# Appendixes

Appendix A. Exact Search Strings

Appendix B. Forms/Guides

Appendix C. Evidence Tables

Appendix D. List of Excluded Studies

Appendix E. Technical Expert Panel and Peer Reviewers