# List of Acronyms/Abbreviations

AB | Able bodied
AE | Active exercise
AHRQ | Agency for Healthcare Research and Quality
BMI | Body mass index
C | Cholesterol
CDC | Centers for Disease Control
CI | Confidence interval
CVD | Cardiovascular disease
DXA | Dual energy x-ray absorptiometry
ECG | Electrocardiogram
EPC | Evidence-based Practice Center
FES | Functional electrical stimulation
HDL | High-density lipoprotein
HI | High intensity
HRR | Heart rate reserve
ICD | International classification of diseases
IGT | Impaired glucose tolerance
LBBB | Left bundle branch blocks
LDL | Low-density lipoprotein
LI | Low intensity
LVH | Left ventricular hypertrophy
MET | Metabolic equivalents
N | Number
NA | Not applicable
OGTT | Oral glucose tolerance test
OR | Odds ratio
PE | Passive exercise
RCT | Randomized controlled trial
SCI | Spinal cord injury
TC | Total cholesterol
TEP | Technical expert panel
TG | Triglycerides
VA | Veterans Affairs
VHA | Veterans Health Administration
WAFT | Wheelchair aerobic fitness trainer
WMD | Weighted mean difference