# References and Included Studies

(Note that there is a separate set of references at the end of the evidence tables in Appendix E and reference numbers are different than those in the text of the report)

1 Hartkopp A, Bronnum-Hansen H, Seidenschnur AM, et al. Survival and cause of death after traumatic spinal cord injury. A long-term epidemiological survey from Denmark. Spinal Cord. Feb. 1997;35(2):76-85. [pmid: 9044513].
2 DeVivo MJ, Black KJ, Stover SL. Causes of death during the first 12 years after spinal cord injury. Arch Phys Med Rehabil. Mar. 1993;74(3):248-54. [pmid: 8439250].
3 Rish BL, Dilustro JF, Salazar AM, et al. Spinal cord injury: a 25-year morbidity and mortality study. Mil Med. Feb. 1997;162(2):141-8. [pmid: 9038035].
4 Einhorn D, Reaven GM, Cobin RH, et al. American College of Endocrinology position statement on the insulin resistance syndrome. Endocr Pract. May–Jun. 2003;9(3):237-52. [pmid: 12924350].
5 National Center for Injury Prevention. Injury Fact Book. Atlanta, GA: National Center for Injury Prevention and Control Centers for Disease Control and Prevention; 2006.
6 Liverman CT, Institute of Medicine (U.S.) Committee on Spinal Cord Injury. Spinal cord injury: progress, promise, and priorities. Washington, DC: National Academies Press; 2005.
7 National Institutes of Health National Heart Lung and Blood Institute (NHLBI). Clinical Guidelines on Identification, Evaluation, and Treatment of Overweight and Obesity in Adults: The Evidence Report September 1998. NIH publication No. 98-4083.
8 Skelza WM, Kalpakiian CZ, Zemper ED, et al. Perceived barriers to exercise in people with spinal cord injury. Am J Phys Med Rehabil. 2005;84(8):576-83. [pmid: 16034226].
9 Strauss DJ, Devivo MJ, Paculdo DR, et al. Trends in life expectancy after spinal cord injury. Arch Phys Med Rehabil. Aug. 2006;87(8):1079-85. [pmid: 16876553].
10 Bauman WA, Spungen AM, Raza M, et al. Coronary artery disease: metabolic risk factors and latent disease in individuals with paraplegia. Mount Sinai Journal of Medicine. 1992;59(2):163-8. [pmid: 1574072].
11 Field M, Jette A, Martin L. Workshop on Disability in America, a New Look summary and papers: Based on a workshop of the Committee on Disability in America: a New Look, Board on Health Sciences Policy.: National Academies Press; 2006.
12 DeVivo MJ, Shewchuk RM, Stover SL, et al. A cross-sectional study of the relationship between age and current health status for persons with spinal cord injuries. Paraplegia. Dec. 1992;30(12):820-7. [pmid: 1287535].
13 Manns PJ, McCubbin JA, Williams DP. Fitness, inflammation, and the metabolic syndrome in men with paraplegia. Arch Phys Med Rehabil. Jun. 2005;86(6):1176-81. [pmid: 15954057].
14 Jones LM, Legge M, Goulding A. Factor analysis of the metabolic syndrome in spinal cord-injured men. Metabolism. Oct. 2004;53(10):1372-7. [pmid: 15375797].
15 Lee MY, Myers J, Hayes A, et al. C-reactive protein, metabolic syndrome, and insulin resistance in individuals with spinal cord injury. J Spinal Cord Med. 2005;28(1):20-5. [pmid: 15832900].
16 Bauman WA, Adkins RH, Spungen AM, et al. The effect of residual neurological deficit on serum lipoproteins in individuals with chronic spinal cord injury. Spinal Cord. Jan. 1998;36(1):13-7. [pmid: 9471131].
17 Bauman WA, Adkins RH, Spungen AM, et al. Ethnicity effect on the serum lipid profile in persons with spinal cord injury. Arch Phys Med Rehabil. Feb. 1998;79(2):176-80. [pmid: 9474000].
18 Lee CS, Lu YH, Lee ST, et al. Evaluating the prevalence of silent coronary artery disease in asymptomatic patients with spinal cord injury. Int Heart J. May. 2006;47(3):325-30. [pmid: 16823238].
19 Myslinski MJ. Evidence-based exercise prescription for individuals with spinal cord injury. J Neurol Phys Ther. Jun. 2005;29(2):104-6. [pmid: 16386166].
20 Szlachcic Y, Adkins RH, Adal T, et al. The effect of dietary intervention on lipid profiles in individuals with spinal cord injury. J Spinal Cord Med. Spring. 2001;24(1):26-9. [pmid: 11587431].
21 Moussavi RM, Ribas-Cardus F, Rintala DH, et al. Dietary and serum lipids in individuals with spinal cord injury living in the community. J Rehabil Res Dev. Mar–Apr. 2001;38(2):225-33. [pmid: 11392655].
22 Bracken MB. Pharmacological treatment of acute spinal cord injury: current status and future projects. J Emerg Med. 1993;11(Suppl 1):43-8. [pmid: 8445202].
23 Dorizzi A. Guidelines for management of spinal cord injury. Spinal Surgery Study Group of the Italian Society of Neurosurgery. J Neurosurg Sci. Jun. 1997;41(2):133-8. [pmid: 9385563].
24 Maynard FM Jr, Bracken MB, Creasey G, et al. International Standards for Neurological and Functional Classification of Spinal Cord Injury. American Spinal Injury Association. Spinal Cord. May. 1997;35(5):266-74. [pmid: 9160449].
25 Biddle AK, Fraher EP. Developing clinical practice guidelines for spinal cord medicine. Lessons learned. Phys Med Rehabil Clin N Am 2000 Feb; 11(1):227–43, x–xi.
26 Jacobs PL, Nash MS. Exercise recommendations for individuals with spinal cord injury. Sports Med. 2004;34(11):727-51. [pmid: 15456347].
27 Nash MS. Exercise as a health-promoting activity following spinal cord injury. J Neurol Phys Ther 2005 Jun; 29(2):87–103, 6.
28 Bauman WA, Adkins RH, Spungen AM, et al. The effect of residual neurological deficit on oral glucose tolerance in persons with chronic spinal cord injury. Spinal Cord. Nov. 1999;37(11):765-71. [pmid: 10578247].
29 Bauman WA, Spungen AM. Disorders of carbohydrate and lipid metabolism in veterans with paraplegia or quadriplegia: a model of premature aging. Metabolism. Jun. 1994;43(6):749-56. [pmid: 8201966].
30 Imai K, Kadowaki T, Aizawa Y, et al. Morbidity rates of complications in persons with spinal cord injury according to the site of injury and with special reference to hypertension. Paraplegia. Apr. 1994;32(4):246-52. [pmid: 8022634].
31 Zhong YG, Levy E, Bauman WA. The relationships among serum uric acid, plasma insulin, and serum lipoprotein levels in subjects with spinal cord injury. Horm Metab Res. Jun. 1995;27(6):283-6. [pmid: 7557840].
32 Imai K, Kadowaki T, Aizawa Y, et al. Problems in the health management of persons with spinal cord injury. J Clin Epidemiol. May. 1996;49(5):505-10. [pmid: 8636723].
33 Charlifue SW, Weitzenkamp DA, Whiteneck GG. Longitudinal outcomes in spinal cord injury: aging, secondary conditions, and well-being. Arch Phys Med Rehabil. Nov. 1999;80(11):1429-34. [pmid: 10569437].
34 Prakash M, Raxwal V, Froelicher VF, et al. Electrocardiographic findings in patients with chronic spinal cord injury. Am J Phys Med Rehabil. Aug. 2002;81(8):601-8. [pmid: 12172070].
35 Frisbie JH. Diabetes mellitus and preventable spinal cord injury. J Spinal Cord Med. 2005;28(1):60-3. [pmid: 15832905].
36 Garshick E, Kelley A, Cohen SA, et al. A prospective assessment of mortality in chronic spinal cord injury. Spinal Cord. Jul. 2005;43(7):408-16. [pmid: 15711609]. [pmcid: 1298182].
37 Lavela SL, Weaver FM, Goldstein B, et al. Diabetes mellitus in individuals with spinal cord injury or disorder. J Spinal Cord Med. 2006;29(4):387-95. [pmid: 17044389]. [pmcid: 1864854].
38 Bauman WA, Spungen AM, Zhong YG, et al. Depressed serum high density lipoprotein cholesterol levels in veterans with spinal cord injury. Paraplegia. Oct. 1992;30(10):697-703. [pmid: 1448297].
39 Krum H, Howes LG, Brown DJ, et al. Risk factors for cardiovascular disease in chronic spinal cord injury patients. Paraplegia. Jun. 1992;30(6):381-8. [pmid: 1635786].
40 Bauman WA, Adkins RH, Spungen AM, et al. Is immobilization associated with an abnormal lipoprotein profile? Observations from a diverse cohort. Spinal Cord. Jul. 1999;37(7):485-93. [pmid: 10438115].
41 Anson CA, Shepherd C. Incidence of secondary complications in spinal cord injury. Int J Rehabil Res. Mar. 1996;19(1):55-66. [pmid: 8730544].
42 Spungen AM, Adkins RH, Stewart CA, et al. Factors influencing body composition in persons with spinal cord injury: a cross-sectional study. J Appl Physiol. Dec. 2003;95(6):2398-407. [pmid: 12909613].
43 Johnston MV, Diab ME, Chu BC, et al. Preventive services and health behaviors among people with spinal cord injury. J Spinal Cord Med. 2005;28(1):43-54. [pmid: 15832903].
44 Gupta N, White KT, Sandford PR. Body mass index in spinal cord injury — a retrospective study. Spinal Cord. Feb. 2006;44(2):92-4. [pmid: 16030513].
45 Weaver FM, Collins EG, Kurichi J, et al. Prevalence of obesity and high blood pressure in veterans with spinal cord injuries and disorders: a retrospective review. Am J Phys Med Rehabil. Jan. 2007;86(1):22-9. [pmid: 17304685].
46 Cardus D, Ribas-Cardus F, McTaggart WG. Coronary risk in spinal cord injury: assessment following a multivariate approach. Arch Phys Med Rehabil. Oct. 1992;73(10):930-3. [pmid: 1417469].
47 Nam CC, Odderson IR. Stroke in the spinal cord injured. J Am Paraplegia Soc. Jan. 1994;17(1):36-8. [pmid: 8169603].
48 McGlinchey-Berroth R, Morrow L, Ahlquist M, et al. Late-life spinal cord injury and aging with a long term injury: characteristics of two emerging populations. J Spinal Cord Med. Jul. 1995;18(3):183-93. [pmid: 7552423].
49 DeVivo MJ, Krause JS, Lammertse DP. Recent trends in mortality and causes of death among persons with spinal cord injury. Arch Phys Med Rehabil. Nov. 1999;80(11):1411-9. [pmid: 10569435].
50 Cardenas DD, Hoffman JM, Kirshblum S, et al. Etiology and incidence of rehospitalization after traumatic spinal cord injury: a multicenter analysis. Arch Phys Med Rehabil. Nov. 2004;85(11):1757-63. [pmid: 15520970].
51 Lee MY, Myers J, Abella J, et al. Homocysteine and hypertension in persons with spinal cord injury. Spinal cord: the official journal of the International Medical Society of Paraplegia. 2006;44(8):474-9. [pmid: 16331308].
52 Whiteneck GG, Charlifue SW, Frankel HL, et al. Mortality, morbidity, and psychosocial outcomes of persons spinal cord injured more than 20 years ago. Paraplegia. Sep. 1992;30(9):617-30. [pmid: 1408338].
53 Groah SL, Weitzenkamp D, Sett P, et al. The relationship between neurological level of injury and symptomatic cardiovascular disease risk in the aging spinal injured. Spinal Cord. Jun. 2001;39(6):310-7. [pmid: 11438852].
54 Davies DS, McColl MA. Lifestyle risks for three disease outcomes in spinal cord injury. Clin Rehabil. Feb. 2002;16(1):96-108. [pmid: 11837530].
55 Levi R, Hultling C, Seiger A. The Stockholm Spinal Cord Injury Study. 3. Health-related issues of the Swedish annual level-of-living survey in SCI subjects and controls. Paraplegia. Dec. 1995;33(12):726-30. [pmid: 8927413].
56 Levi R, Hultling C, Seiger A. The Stockholm Spinal Cord Injury Study: 2. Associations between clinical patient characteristics and post-acute medical problems. Paraplegia. Oct. 1995;33(10):585-94. [pmid: 8848313].
57 Duran FS, Lugo L, Ramirez L, et al. Effects of an exercise program on the rehabilitation of patients with spinal cord injury. Arch Phys Med Rehabil. Oct. 2001;82(10):1349-54. [pmid: 11588736].
58 de Groot PC, Hjeltnes N, Heijboer AC, et al. Effect of training intensity on physical capacity, lipid profile and insulin sensitivity in early rehabilitation of spinal cord injured individuals. Spinal Cord. Dec. 2003;41(12):673-9. [pmid: 14639446].
59 El-Sayed MS, Younesian A. Lipid profiles are influenced by arm cranking exercise and training in individuals with spinal cord injury. Spinal Cord. May. 2005;43(5):299-305. [pmid: 15583706].
60 Midha M, Schmitt JK, Sclater M. Exercise effect with the wheelchair aerobic fitness trainer on conditioning and metabolic function in disabled persons: a pilot study. Arch Phys Med Rehabil. Mar. 1999;80(3):258-61. [pmid: 10084432].
61 Nash MS, Jacobs PL, Mendez AJ, et al. Circuit resistance training improves the atherogenic lipid profiles of persons with chronic paraplegia. J Spinal Cord Med. Spring. 2001;24(1):2-9. [pmid: 11587430].
62 Phillips SM, Stewart BG, Mahoney DJ, et al. Body-weight-support treadmill training improves blood glucose regulation in persons with incomplete spinal cord injury. J Appl Physiol. Aug. 2004;97(2):716-24. [pmid: 15107410].
63 Stewart BG, Tarnopolsky MA, Hicks AL, et al. Treadmill training-induced adaptations in muscle phenotype in persons with incomplete spinal cord injury. Muscle Nerve. Jul. 2004;30(1):61-8. [pmid: 15221880].
64 Chilibeck PD, Bell G, Jeon J, et al. Functional electrical stimulation exercise increases GLUT-1 and GLUT-4 in paralyzed skeletal muscle. Metabolism. Nov. 1999;48(11):1409-13. [pmid: 10582549].
65 Hjeltnes N, Galuska D, Bjornholm M, et al. Exercise-induced overexpression of key regulatory proteins involved in glucose uptake and metabolism in tetraplegic persons: molecular mechanism for improved glucose homeostasis. Faseb J. Dec. 1998;12(15):1701-12. [pmid: 9837860].
66 Jeon JY, Weiss CB, Steadward RD, et al. Improved glucose tolerance and insulin sensitivity after electrical stimulation-assisted cycling in people with spinal cord injury. Spinal Cord. Mar. 2002;40(3):110-7. [pmid: 11859437].
67 Mahoney ET, Bickel CS, Elder C, et al. Changes in skeletal muscle size and glucose tolerance with electrically stimulated resistance training in subjects with chronic spinal cord injury. Arch Phys Med Rehabil. Jul. 2005;86(7):1502-4. [pmid: 16003691].
68 Mohr T, Dela F, Handberg A, et al. Insulin action and long-term electrically induced training in individuals with spinal cord injuries. Med Sci Sports Exerc. Aug. 2001;33(8):1247-52. [pmid: 11474322].
69 Dallmeijer AJ, Hopman MT, van der Woude LH. Lipid, lipoprotein, and apolipoprotein profiles in active and sedentary men with tetraplegia. Arch Phys Med Rehabil. Nov. 1997;78(11):1173-6. [pmid: 9365344].
70 Dallmeijer AJ, van der Woude LH, van Kamp GJ, et al. Changes in lipid, lipoprotein and apolipoprotein profiles in persons with spinal cord injuries during the first 2 years post-injury. Spinal Cord. Feb. 1999;37(2):96-102. [pmid: 10065747].
71 Janssen TW, van Oers CA, van Kamp GJ, et al. Coronary heart disease risk indicators, aerobic power, and physical activity in men with spinal cord injuries. Arch Phys Med Rehabil. Jul. 1997;78(7):697-705. [pmid: 9228871].
72 Chen Y, Henson S, Jackson AB, et al. Obesity intervention in persons with spinal cord injury. Spinal Cord. Feb. 2006;44(2):82-91. [pmid: 16103891].
73 American Diabetes Association. Standards of medical care in diabetes—2006. Diabetes Care. Jan. 2006;29(Suppl 1):S4-42. [pmid: 16373931].
74 Agha Z, Lofgren RP, Van Ruiswyk JV, et al. Are patients at Veterans Affairs medical centers sicker? A comparative analysis of health status and medical resource use. Arch Intern Med. Nov 27. 2000;160(21):3252-7. [pmid: 11088086].
75 Ozgurtas T, Alaca R, Gulec M, et al. Do spinal cord injuries adversely affect serum lipoprotein profiles?. Mil Med. Jul. 2003;168(7):545-7. [pmid: 12901464].
76 Myers J, Lee M, Kiratli J. Cardiovascular disease in spinal cord injury: an overview of prevalence, risk, evaluation, and management. Am J Phys Med Rehabil. Feb. 2007;86(2):142-52. [pmid: 17251696].
77 O'Rourke RA. Should patients with type 2 diabetes asymptomatic for coronary artery disease undergo testing for myocardial ischemia?. Nat Clin Pract Cardiovasc Med. Oct. 2005;2(10):492-3. [pmid: 16186827].
78 Heller GV. Evaluation of the patient with diabetes mellitus and suspected coronary artery disease. Am J Med. Apr. 2005;118(Suppl 2):9S-14S. [pmid: 15903290].
79 Khastgir J, Drake MJ, Abrams P. Recognition and effective management of autonomic dysreflexia in spinal cord injuries. Expert Opin Pharmacother. May. 2007;8(7):945-56. [pmid: 17472540].
80 Collins HL, Rodenbaugh DW, DiCarlo SE. Spinal cord injury alters cardiac electrophysiology and increases the susceptibility to ventricular arrhythmias. Progress in Brain Research. 2006;152:275-88. [pmid: 16198707].
81 Lidal IB, Snekkevik H, Aamodt G, et al. Mortality after spinal cord injury in Norway. J Rehabil Med. Mar. 2007;39(2):145-51. [pmid: 17351697].
82 Bolen S, Feldman L, Vassy J, et al. Systematic review: comparative effectiveness and safety of oral medications for type 2 diabetes mellitus. Ann Intern Med. Sep 18. 2007;147(6):386-99. [pmid: 17638715].
83 Singh S, Loke YK, Furberg CD. Long-term risk of cardiovascular events with rosiglitazone: a meta-analysis. JAMA. Sep 12. 2007;298(10):1189-95. [pmid: 17848653].
84 Lincoff AM, Wolski K, Nicholls SJ, et al. Pioglitazone and risk of cardiovascular events in patients with type 2 diabetes mellitus: a meta-analysis of randomized trials. JAMA. Sep 12. 2007;298(10):1180-8. [pmid: 17848652].
85 Washburn RA, Figoni SF. High density lipoprotein cholesterol in individuals with spinal cord injury: the potential role of physical activity. Spinal Cord. Oct. 1999;37(10):685-95. [pmid: 10557124].
86 Sigal RJ, Kenny GP, Boule NG, et al. Effects of aerobic training, resistance training, or both on glycemic control in type 2 diabetes: a randomized trial. Ann Intern Med. Sep 18. 2007;147(6):357-69. [pmid: 17876019].
87 Kodama S, Tanaka S, Saito K, et al. Effect of aerobic exercise training on serum levels of high-density lipoprotein cholesterol: a meta-analysis. Arch Intern Med. May 28. 2007;167(10):999-1008. [pmid: 17533202].
88 Lakka TA, Laaksonen DE, Lakka HM, et al. Sedentary lifestyle, poor cardiorespiratory fitness, and the metabolic syndrome. Med Sci Sports Exerc. Aug. 2003;35(8):1279-86. [pmid: 12900679].
89 Ekelund U, Brage S, Franks PW, et al. Physical activity energy expenditure predicts progression toward the metabolic syndrome independently of aerobic fitness in middle-aged healthy Caucasians: the Medical Research Council Ely Study. Diabetes Care. May. 2005;28(5):1195-200. [pmid: 15855588].
90 Katzmarzyk PT, Church TS, Janssen I, et al. Metabolic syndrome, obesity, and mortality: impact of cardiorespiratory fitness. Diabetes Care. Feb. 2005;28(2):391-7. [pmid: 15677798].
91 Blair SN, Kampert JB, Kohl HW 3rd, et al. Influences of cardiorespiratory fitness and other precursors on cardiovascular disease and all-cause mortality in men and women. JAMA. Jul 17. 1996;276(3):205-10. [pmid: 8667564].
92 Pate RR, Pratt M, Blair SN, et al. Physical activity and public health. A recommendation from the Centers for Disease Control and Prevention and the American College of Sports Medicine. JAMA. Feb 1. 1995;273(5):402-7. [pmid: 7823386].
93 Ginis KA, Hicks AL. Exercise research issues in the spinal cord injured population. Exerc Sport Sci Rev. Jan. 2005;33(1):49-53. [pmid: 15640721].
94 Figoni SF. Spinal Cord Injury. In: Durstine JL, ed. Exercise management for persons with chronic diseases and disabilities. Champaign, IL: Human Kinetics; 1997; 175–9.
95 Moore DS, McCabe GP. Introduction to the practice of statistics. 4th ed. New York: W.H. Freeman and Co.; 2003.
96 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. Jun 15. 2002;21(11):1539-58. [pmid: 12111919].
97 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
98 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med 2006 Feb 6.
99 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
100 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. Sep 6. 2003;327(7414):557-60. [pmid: 12958120]. [pmcid: 192859].
101 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London: NetLibrary, Inc. BMJ Books; 2001.
102 Cowie CC, Rust KF, Byrd-Holt DD, et al. Prevalence of diabetes and impaired fasting glucose in adults in the U.S. population: National Health And Nutrition Examination Survey 1999-2002. Diabetes Care. Jun. 2006;29(6):1263-8. [pmid: 16732006].
103 Bauman WA, Kahn NN, Grimm DR, et al. Risk factors for atherogenesis and cardiovascular autonomic function in persons with spinal cord injury. Spinal Cord. Sep. 1999;37(9):601-16. [pmid: 10490851].
104 Flegal KM, Carroll MD, Ogden CL, et al. Prevalence and trends in obesity among US adults, 1999-2000. JAMA. Oct 9. 2002;288(14):1723-7. [pmid: 12365955].
105 Flegal KM, Graubard BI, Williamson DF, et al. Excess deaths associated with underweight, overweight, and obesity. JAMA. Apr 20. 2005;293(15):1861-7. [pmid: 15840860].
106 Bauman WA, Raza M, Chayes Z, et al. Tomographic thallium-201 myocardial perfusion imaging after intravenous dipyridamole in asymptomatic subjects with quadriplegia. Arch Phys Med Rehabil. Jul. 1993;74(7):740-4. [pmid: 8328897].
107 Bauman WA, Raza M, Spungen AM, et al. Cardiac stress testing with thallium-201 imaging reveals silent ischemia in individuals with paraplegia. Arch Phys Med Rehabil. Sep. 1994;75(9):946-50. [pmid: 8085927].
108 Orakzai SH, Orakzai RH, Ahmadi N, et al. Measurement of coronary artery calcification by electron beam computerized tomography in persons with chronic spinal cord injury: evidence for increased atherosclerotic burden. Spinal Cord 2007 Mar 6.
109 Weaver FM, Smith B, Evans CT, et al. Outcomes of outpatient visits for acute respiratory illness in veterans with spinal cord injuries and disorders. Am J Phys Med Rehabil. Sep. 2006;85(9):718-26. [pmid: 16924184].
110 Washburn RA, Figoni SF. Physical activity in chronic cardiovascular disease prevention in spinal cord injury: A comprehensive literature review. Top Spinal Cord Inj Rehabil. 1998;3(3):16-32.