# Executive Summary

## Introduction

Spinal cord injuries (SCI) result in 11,000 hospitalizations of new cases annually in the United States.^5,^ ^6^ More than 240,000 Americans live with a disability related to SCI and the estimated annual cost averages $9.7 billion.^5,^ ^7,^ ^8^ Improved quality of care over the last several decades has resulted in a 40 percent decline in mortality during the two years following the injury.^9^ However, improvement in long-term survival has been smaller. Cardiovascular diseases (CVD) have been reported as the most common cause of death in adults with chronic SCI.^2,^ ^10^–^12^ CVD risk factors associated with SCI include behavior (smoking, limited exercise) and metabolic abnormalities (obesity, metabolic syndrome,^13^–^15^ and diabetes^11^). The prevalence of dyslipidemia^16,^ ^17^ and coronary heart disease has been reported to be higher in adults with SCI compared to the general population.^10,^ ^18^ The Institute of Medicine recently released two reports that emphasized the role of cardiovascular risk assessment and management in adults with chronic SCI.^6,^ ^11^ Some evidence suggests that exercise,^19^ diet,^20,^ ^21^ and pharmacological therapy^22^ may reduce diabetes and CVD risk in these individuals. Furthermore, markers or thresholds of carbohydrate and lipid disorders commonly used in adults without SCI may not apply to the population that has sustained SCI. In particular, because adults with SCI lose muscle mass that is replaced with fat mass, traditional measures of obesity (weight or body mass index [BMI]) may not be appropriate.

Accurate estimates of diabetes prevalence and severity in adults with SCI may: 1) be underestimated relative to able-bodied controls because individuals with SCI may not undergo regular testing, 2) have lower levels of high-density lipoprotein (HDL) cholesterol that go unrecognized if providers only assess total cholesterol (TC) levels or base treatment solely on low-density lipoprotein (LDL) cholesterol, or 3) they have earlier evidence of impaired glucose tolerance or altered insulin sensitivity. Existing guidelines do not include routine evaluation of glucose and lipid abnormalities nor do they provide recommendations for threshold definitions of abnormality or target levels for interventions to achieve it.^23^–^25^ Furthermore, the prevalence, morbidity, and mortality associated with carbohydrate and lipid disorders may differ in adults with SCI compared to able-bodied individuals.

Effective interventions to treat carbohydrate and lipid disorders and reduce cardiovascular complications in able-bodied individuals include dietary, pharmacologic, and exercise therapies. However, adults with SCI have unique physiologic characteristics that may preclude generalization of evidence from able-bodied individuals to those with SCI. Total daily energy expenditure for adults with SCI is difficult to calculate but likely much lower than for able-bodied individuals, especially among individuals requiring motorized wheelchairs for mobility. Treatment of obesity in SCI remains largely empiric, including guidelines developed for dietary intervention in SCI. Pharmacologic therapies to alter carbohydrate and lipid disorders may have different effectiveness and adverse effects in individuals with SCI compared to able-bodied patients. For example, assessment of hepatic or muscle toxicity in SCI individuals may be difficult using traditional serologic measures developed in able-bodied adults because SCI individuals have reduced muscle mass and potentially altered hepatic metabolism.

Despite the expected benefits of exercise for individuals with SCI, this group also faces unique challenges and risks from exercise that are not experienced by the able-bodied population.^8,^ ^26^ For one, lack of access to and choices in exercise modes, depending on the neurological impact and level of the injury, form physical barriers to obtaining exercise. Physiological risks of exercise are also a barrier to improved fitness among those with SCI. Depending on the level and completeness of the spinal injury, motor, sensory, and autonomic reflexes may still be intact but no longer under control of the brain. Individuals with SCI also experience various types of autonomic and circulatory dysregulation.^26^ Risk of stress-related musculoskeletal injury is of concern, given the reliance on a small group of muscles for activities of daily living as well as for any physical conditioning. Fractures, joint dislocation, and overuse injuries are common for individuals with SCI.^27^

We conducted a systematic review of published evidence to address the following questions:

Question 1a: What proportion of adult patients with chronic posttraumatic spinal cord injuries have been diagnosed with:

a Insulin resistance syndrome, metabolic syndrome
b Diabetes mellitus Type 2, impaired glucose tolerance
c Dyslipidemia
d Obesity

Question 1b: Is the prevalence of carbohydrate and lipid disorders higher in the subgroups of patients by age, race, and gender compared to the general population? Does the prevalence of carbohydrate and lipid disorders differ by the time after trauma, the level of trauma, and functional impairment?

Question 2: For people with SCI, what is the evidence on contribution to risk of cardiovascular disease of:

a Hyperinsulinemia
b Abnormalities in carbohydrate metabolism
c Abnormalities in lipid metabolism?
d Obesity

This question was refined as:

Question 2: Regarding risk of cardiovascular disease for people with SCI:

a What is cardiovascular prevalence and mortality in adults with chronic posttraumatic spinal cord injuries?
b Does cardiovascular incidence and mortality in adults with chronic posttraumatic spinal cord injuries differ compared to the general population based on age, race, and gender categories?
c What is the strength of the association between cardiovascular incidence and mortality and abnormalities in lipid and glucose metabolism including Type 2 diabetes mellitus after adjustment for possible confounding factors?
d Does association vary depending on age, gender, race, the duration after SCI, the level of SCI, and functional impairment?

Question 3: What are the effects on carbohydrate or lipid-related outcomes in adults with SCI of:

a Exercise
b Dietary and pharmacologic interventions

## Methods

Studies addressing prevalence of obesity, diabetes, impaired glucose tolerance, insulin resistance, and lipid disorders through August 2007 were included if:

1 adults had chronic SCI;
2 the total number of spinal cord subjects was at least 100, or totaling at least 100 subjects if a control group was included (SCI + controls ≥100);
3 reported prevalence of obesity, diabetes, impaired glucose tolerance, metabolic syndrome or insulin resistance, or lipid disorders or reported mean BMI or lipid levels,
4 were published in the English language. Abstracts of articles excluded due to small sample size were reviewed to assess for study quality and potential impact.

For Question 2, original epidemiologic investigations of more than 50 adults with chronic SCI and published in English after 1990 were identified in MEDLINE^®^ via PubMed® and the Cochrane library. Websites of the American Spinal Injury Association, American Paraplegia Society, Paralyzed Veterans of America, Consortium of Spinal Cord Medicine, and the catalog WorldCat identified reviews.

For exercise interventions, the Endnote library containing original and review articles (n=2,212) was searched for abstracts that included the words fitness, physical activity, or exercise, resulting in a subset of 303 citations. A MEDLINE^®^ search was conducted of articles written in English and published between 1996 and August 2007. Any identified study was included regardless of design, sample size, or duration if it reported carbohydrate, lipid, or cardiovascular results in adults with chronic SCI.

To assess dietary or pharmacologic interventions for treatment of carbohydrate and lipid metabolism disorders in the SCI population, studies were identified by searching in MEDLINE^®^ through October 2007. Reference lists of included studies or reviews were also searched. Since no randomized trials were identified, nonrandomized studies were eligible. To be included, studies had to:

1 evaluate adults who had chronic SCI, defined as one year or more since sustaining the injury;
2 evaluate pharmacologic or dietary interventions;
3 report carbohydrate and/or lipid-related outcome measures; and
4) be published in the English language.

Reviewers extracted study and patient characteristics and outcomes onto standardized forms. A second reviewer assessed the findings and disagreements, while rare, were resolved by discussion. Prevalence estimates of obesity, diabetes, lipid disorders, and cardiovascular morbidity and mortality among adults with SCI and, where possible, able-bodied controls, are presented. Findings are reported separately where possible according to age, gender, race, and level/severity of SCI. For Question 3, carbohydrate and lipid outcomes are described according to the exercise, diet, or pharmacologic intervention studied. Due to heterogeneity in populations, interventions, comparator groups, and/or reported outcomes, pooled analyses was generally not conducted.

## Results

For Question 1, 23 studies met the inclusion criteria, two studies for insulin resistance/ metabolic syndrome,^15,^ ^28^ 12 studies for diabetes mellitus,^3,^ ^15,^ ^28^–^37^ three studies for impaired glucose tolerance,^28,^ ^29,^ ^31^ seven studies for lipid disorders,^16,^ ^17,^ ^21,^ ^31,^ ^38^–^40^ and ten studies for obesity and body composition.^28,^ ^31,^ ^36,^ ^38,^ ^40^–^45^ Potentially eligible studies excluded due to small sample size that limited generalizability (n=45, number of SCI individuals in each study ranged from 1–77) were also of low quality and relevance because they were from a single center, not from the United States, lacked controls, and/or did not assess clinically relevant carbohydrate and lipid disorders.

For Question 2, 20 articles of 19 studies met inclusion criteria; most were conducted in the United States.^1^–^3,^ ^30,^ ^32,^ ^34,^ ^36,^ ^37,^ ^39,^ ^46^–^56^ Studies included more than 50,000 patients with SCI. Males (pooled prevalence 86 percent) and Caucasians comprised the majority of individuals. Most used general population controls, were uncontrolled, or did not adjust for known confounding variables including: age, race, gender, smoking status, exercise, or duration of followup. Wide variation existed in the definitions of reported CVD outcomes.

For Question 3a, studies evaluating the following types of exercise were identified: Active Exercise (AE) (seven studies),^57^–^63^ Functional Electrical Stimulation exercise (FES) (five studies),^64^–^68^ Passive Exercise (PE) (no studies, Self-Reported Physical Activity (six studies),^13,^ ^14,^ ^54,^ ^69^–^71^ and Other (one study).^72^

For Question 3b, only two prospective studies (neither randomized) evaluating dietary and/or lifestyle interventions to reduce lipid levels met inclusion criteria.^20,^ ^72^

### Prevalence of Carbohydrate and Lipid Disorders

The prevalence of insulin resistance, metabolic syndrome, diabetes mellitus, impaired glucose tolerance, dyslipidemia, and obesity in a population are all highly dependent upon demographics of the population including age, socioeconomic status, and race/ethnicity. The dependence of these conditions on population characteristics makes it difficult to conduct between-study comparisons since population characteristics varied greatly, both between and within studies.

Insulin resistance/metabolic syndrome. There was little data on the prevalence of insulin resistance/metabolic syndrome in adults with SCI. There are no high-quality data to determine if insulin resistance or metabolic syndrome are elevated in adults with SCI compared to similar individuals without SCI because no studies included a non-SCI control or comparison group. Only two studies assessed the prevalence of insulin resistance. The one study that provided results by severity of injury showed increased hyperinsulemia in persons with tetraplegia compared to paraplegia following a glucose challenge.^28^ The only study assessing metabolic syndrome was small, uncontrolled, and used definitions for specific metabolic disorders likely to increase the estimated prevalence of the disorders and therefore their estimated prevalence of metabolic syndrome. Their definitions are not widely recommended.^15,^ ^73^

Diabetes mellitus or impaired glucose tolerance (IGT). The prevalence of diabetes appeared higher on average in SCI populations studied compared to the general population. However, there is credible scientific reason to believe that the general population groups selected were not appropriate controls for the studied SCI individuals. For example, lifestyle and comorbidities, irrespective of SCI, could be quite different. Therefore, the extent to which the observed increased prevalence of diabetes is due to a causal relationship between the SCI and the development of subsequent diabetes is not known. Overall, control groups comprised of veterans using Veterans Affairs (VA) medical centers for health care tended to be similar to VA SCI populations in their rate of diabetes. Only when the rate of diabetes in the VA SCI group was compared to the general public did the SCI individuals appear to be at higher risk. Users of the VA health care system have greater comorbidities than either veterans not using the VA health care system or non-VA populations. Therefore, current evidence is insufficient to determine to what extent the higher rate of diabetes is independently attributable to SCI or to other factors that might be higher in adults who subsequently have a SCI than in the general public. There was little evidence suggesting that fasting plasma glucose was elevated in adults with SCI. There was some evidence that adults with SCI may be more likely to meet IGT or diabetes diagnostic criteria following oral glucose tolerance tests (OGTT). However, no studies reported repeated OGTT.

Lipid disorders. There is some evidence that individuals with SCI compared to controls may possess favorably lower average TC (three studies n = 1,427; weighted mean difference (WMD) = -14.3 mg/dL [95 percent CI = -22.2, 6.4]),^38^–^40^ LDL cholesterol (two studies, n = 773 WMD = -10.77 [95 percent CI = -16.0, -5.6]),^38,^ ^40^ and triglyceride levels (two studies n = 773; WMD = -10.0 mg/dL [95 percent CI = -18.3, 1.6]).^38,^ ^40^ HDL cholesterol was lower in SCI individuals compared to controls (three studies n = 1,427; WMD = -7.6 mg/dL [95 percent CI = -10.6, 4.6]), though confidence intervals were wide and results not statistically significant.^38^–^40^

Obesity and body composition. While BMI is unlikely to be an accurate measure of obesity in the SCI population, it is by far the predominant measure reported in research studies of the prevalence of obesity. There is no high quality evidence that obesity defined by BMI is elevated in individuals with SCI compared to appropriately matched controls. There is some evidence that when obesity is measured as percent body fat, individuals with SCI may be at elevated risk. However, the absence of validated measures of body composition in SCI individuals or large studies that include accurate measurements of body fat precludes stronger conclusions regarding the prevalence of obesity and the impact of injury type and duration on obesity.

### Cardiovascular Prevalence and Mortality in Adults with SCI

CVD prevalence among SCI individuals ranged from 1–3 percent in the majority of studies,^32,^ ^50,^ ^52,^ ^53,^ ^55^ with an increase to 19 percent in older patients and to 14 percent in those 30 or more years after injury.^52^ The prevalence of cerebrovascular diseases was 1–2 percent^3,^ ^39,^ ^53^ and coronary heart disease ≤2 percent,^32,^ ^39,^ ^53^ being increased to 12 percent among members of Paralyzed Veterans of America.^37^ SCI veterans using VA health care had a higher prevalence of myocardial infarction (14 percent^37^to 25 percent)^48^ than SCI civilians (<5 percent in three studies.^3,^ ^39,^ ^53^ The highest prevalence of 33 percent was reported among veterans who were older than 50 years at the time of injury.^48^

Mortality from CVDs was more consistent than prevalence across five studies that reported this outcome;^1^–^3,^ ^49,^ ^52^ 0.8^49^ to 1.5^2^ per 1,000 injured died from diseases of the arteries; 1^49^ -6 percent^1^ to 10 percent^52^ died from cardiovascular disease. Mortality was higher in men (5.3 percent) compared to women (1 percent)^1^ and in older patients, being the highest after 75 years (10 percent).^52^ Less than 1 percent of SCI patients died from cerebrovascular diseases and stroke,^1,^ ^2,^ ^49^ with higher mortality in men (0.7 percent) than women (0.2 percent).^1^ Mortality from ischemic heart disease was <1 percent in two studies^2,^ ^3^ and 2.5 percent (including 2 percent men) in one European study.^1^ One long-term followup study of VA users reported a two-fold increase in mortality from 5 years (0.4 percent) to 20 years (0.9 percent) after injury.^3^ Lung embolus caused death in 0.7 percent of patients with chronic SCI.^1^

Three studies reported that coronary heart diseases constitute approximately 9 percent among primary causes of death in SCI patients.^1^–^3^ The proportion of deaths attributable to all CVDs varied from 18.8 percent for diseases of the heart^49^ to 24 percent for circulatory system disorders.^1^ Cardiovascular diseases are among the leading causes of death in patients with chronic SCI^1,^ ^49,^ ^52^ however, the contribution of age cannot be estimated analyzing crude proportion of aging SCI patients who died from heart diseases. One study of 402 veterans with chronic SCI followed for 55.6 months^36^ showed that diabetes (relative risk 2.62, 95 percent CI 1.19; 5.77) and heart diseases (relative risk 3.66, 95 percent CI 1.77; 7.78) were significant risk factors for death after adjustment for age.

When compared to able-bodied adults, cardiovascular morbidity in SCI patients did not show significant differences.^34,^ ^39^ Inconsistent and limited evidence suggested that patients with chronic SCI had lower prevalence of congestive heart failure^34^ but no differences in the odds of diabetes, myocardial infraction, angina pectoris, or cerebrovascular diseases.^34,^ ^39,^ ^55^

Diabetes contributed to a higher risk of CVD in veterans with SCI compared to SCI veterans without diabetes. One large study of veterans with SCI, able-bodied veterans, and the general population reported a three times higher rate of diabetes in injured veterans compared to the general population (20 percent vs. 6.7 percent, odds ratio 3.32, 95 percent CI 1.34; 8.26) but similar odds compared to other veterans (21 percent, odds ratio 0.94, 95 percent CI 0.47; 1.87).^37^ Injured veterans with diabetes had higher adjusted rates of coronary heart disease by 280 percent, myocardial infarction by 270 percent, arterial hypertension by 250 percent, and stroke by 230 percent compared to SCI patients without diabetes.^37^ Age may modify the association with injury and diabetes. For example, odds of diabetes were higher in injured veterans compared to the general population in all age groups but higher compared to able-bodied veterans in those ages 45–59, 55–59, and older than 70 years.^37^

Some evidence suggested that neurological functional status may be associated with cardiovascular morbidity.^53^ Patients with tetraplegia and no functional motor preservation had higher age adjusted odds ratio of cerebrovascular diseases, dysrhythmia, and valvular diseases and lower odds ratio of coronary heart disease compared to paraplegic patients.^53^ Injured patients with functional motor preservation had higher age adjusted odds of all CVDs, coronary atherosclerosis, dysrhythmia, and valvular disease.^53^ Some electrocardiogram abnormalities including left bundle branch block, left ventricular hypertrophy with strain, and atrial fibrillation accompanied the higher hazard ratio of death in patients with SCI.^34^ Furthermore, these abnormalities were associated with a greater risk of dying in injured compared to able-bodied patients.^34^

Cardiovascular mortality in injured patients was compared to a standardized by age mortality in the general population in three studies.^1,^ ^2,^ ^36^ Mortality from nonischemic heart diseases (standardized mortality ratio 5.6, 95 percent CI 4.4; 6.8), artery diseases (standardized mortality ratio 4.5 95 percent CI 2.1; 6.9), and lung emboli (standardized mortality ratio 11.4, 95 percent CI 4.2; 24.8) was higher in all injured adults compared to the general population.^1^ Cardiovascular mortality was lower in those injured after 1972 (standardized mortality ratio 2.4 95 percent CI 1.95; 3.01) compared to those injured from 1953-1971 (7.1, 95 percent CI 2.31; 9.32).^1^ Patients with complete tetraplegia died from ischemic heart disease (standardized mortality ratio 2.6, 95 percent CI 1.3; 3.9), nonischemic heart diseases (standardized mortality ratio 23.4, 95 percent CI 16.5; 30.3), and cerebrovascular diseases (standardized mortality ratio 5.4, 95 percent CI 1.8; 9) more often than would be expected from the same age able-bodied adults.^1,^ ^2,^ ^36^

The role of lipid disorders to alter the risk of cardiovascular morbidity and mortality in SCI adults has not been adequately addressed in the published articles. One study concluded that increased blood pressure, elevated blood cholesterol, or smoking could not explain the increased cardiovascular prevalence in SCI patients.^39^ One study showed that diabetes in SCI patients was associated with an increased risk of coronary heart disease, myocardial infarction, arterial hypertension, high cholesterol, and stroke.^37^ The relative risk contribution to adults with SCI compared to able-bodied individuals was not reported.

Diabetes mellitus contributed to an increased risk of cardiovascular diseases compared to individuals with SCI but not having a diagnosis of diabetes.^37^ The relative contribution versus able-bodied individuals is not known. The role of metabolic syndrome had not yet been investigated. Cardiovascular morbidity varied substantially among studies and was highest in injured veterans. Many important confounders might explain such differences beyond the veteran status and many veterans do not receive health care from the VA.^74^ Indirect comparisons of cardiovascular morbidity in adults with SCI with the general population were inadequate to estimate the relative contribution of metabolic disorders in patients with SCI.

### Exercise to Alter Carbohydrate and Lipid Disorders in Adults with SCI

Of the 19 peer reviewed original articles, none were randomized controlled trials (RCTs).^13,^ ^14,^ ^54,^ ^57^–^72^ The majority consisted of small case series or uncontrolled cross-sectional surveys using measures of self-reported physical activity. Six studies (n=57) involved active exercise, five (n=32) assessed functional electrical stimulation, and six studies (n=219) evaluated self-reported physical activity. No studies evaluated passive exercise. Carbohydrate related outcomes were reported in ten studies (n=101) and lipid related measures were reported in 13 studies of 292 individuals. Variation in study design, intervention, and reported outcomes precluded quantitative pooling of results or accurate assessment of efficacy. Evidence on effects of exercise on lipid and carbohydrate metabolism disorders is of poor quality and inconclusive in findings. Studies to date have been short in duration, have involved few subjects, and have relied on study designs highly susceptible to error. None assessed glycosylated hemoglobin.

### Dietary and Pharmacologic Intervention for Carbohydrate or Lipid Outcomes in Adults with SCI

There were no prospective studies that evaluated dietary and/or lifestyle interventions on carbohydrate related outcomes.

Only two poor quality prospective studies evaluated dietary and/or lifestyle interventions to alter lipid levels.^20,^ ^72^ No studies assessing pharmacologic interventions were identified. The two dietary/lifestyle case-series studies included 238 subjects, overwhelmingly male (87 percent).

One controlled trial compared the effect of a dietary intervention referral compared to no dietary referral^20^ over a mean of 16 months. Group 1 subjects were older (mean 42.8 versus 35.7, p<0.0001) and had a longer post-injury duration (15.6 versus 11.1 years, p<0.0001) compared to Group 2 subjects. There were reductions in total and LDL cholesterol levels from baseline in Group 1, 234 to 224 (p<0.001) and 159 to 151 (p=0.004), respectively. Levels increased slightly but not significantly in Group 2. There were no significant effects on HDL cholesterol or triglyceride (TG) levels. An uncontrolled study evaluated a weight management program consisting of 12 classes for 12 weeks, primarily led by a registered dietician.^72^ There were no significant changes in total and LDL cholesterol levels from baseline at weeks 12 and 24. HDL cholesterol was not different at week 24 compared to baseline value.

## Discussion

The present report systematically evaluated published evidence regarding the prevalence of lipid and carbohydrate disorders, CVD, and mortality in adults with chronic posttraumatic SCI. The overall quality of evidence is low. Most studies were retrospective, small, lacked adequate controls, and did not assess or adjust for confounding factors. Outcome measure definitions varied widely. However, limited low quality data suggest that adults with SCI are not at markedly higher risk of carbohydrate and lipid disorders or CVD than age and gender matched able-bodied individuals. Assessment of obesity using BMI is likely to be inaccurate and underestimates body fat in adults with SCI.

The prevalence of insulin resistance, metabolic syndrome, diabetes mellitus, impaired glucose tolerance, dyslipidemia, obesity, and CVD in a population are all highly dependent upon the demographics of the population, including, most importantly, the age distribution, but also socioeconomic status and race/ethnicity. The dependence of these conditions on population characteristics makes it difficult to make between-study comparisons, since the population characteristics range greatly both between and within studies. These factors may explain the wide variation in study prevalence estimates as well as the relative risk compared to different able-bodied control populations.

Some potentially eligible studies (n=45) were excluded due to small sample size (i.e., less than 100 SCI subjects if lacking controls or less than 100 total subjects if including controls). Based on review of published abstracts, the impact of these studies on our overall findings regarding carbohydrate, lipid and body composition disorder prevalence, and subsequent clinical decisionmaking is likely to be small. The number of SCI individuals in the excluded studies ranged from one to 77. Only 17 had control groups. The largest excluded study reporting impaired glucose tolerance and insulin resistance in the United States lacked controls, was comprised of 57 adults from a single center, and was published in 1983. The largest excluded controlled study of lipid disorders was a single center report comprised of 60 young SCI adults (mean age = 28 years) and 28 healthy able-bodied controls matched by age and gender. Serum LDL cholesterol was higher (109 mg/dL vs. 91 mg/dL; p = 0.04) and HDL cholesterol lower (33 mg/dL vs. 44 mg/dL; p =0.004) in SCI adults versus controls. The authors concluded that “serum lipoprotein levels should not be ignored for the followup of patients with spinal cord injury.”^75^ We agree with their conclusion. Other excluded studies were of even lower quality and relevance to health care in the United States because they were smaller, from a single center, not from the United States, lacked controls, and/or did not assess clinically relevant carbohydrate and lipid disorders.

A previous review^76^ suggested a high prevalence of CVD in individuals with SCI. However, this report included, but did not differentiate between, highly prevalent self-reported signs and symptoms, such as leg swelling or palpitations^56^ and less common but more serious conditions or those documented in medical records, such as myocardial infarction (0.28 to 3 percent of SCI patients).^3,^ ^53^ Several factors may contribute to the prevalence of undiagnosed CVD in SCI individuals, including access and quality of care, asymptomatic angina in patients with diabetes or upper level injury,^77,^ ^78^ and metabolic syndrome, unstable blood pressure, and cardiac rhythm.^79,^ ^80^ If screening intensity or criteria to detect/define asymptomatic heart diseases, including coronary heart disease, arrhythmias, and autonomic dysreflexia, differs in SCI compared to able-bodied adults this could bias comparative CVD prevalence estimates.

Prevalence of CVD in aging SCI individuals can be attributable to age rather than injury. Patients differed by the prevalence of risk factors prior to injury and by age at the time of injury. Both could modify the association between SCI and CVD. Indeed, a recently published retrospective analysis found that the presence of cardiovascular disease prior to injury was associated with a 280 percent increase in risk of death.^81^ For each additional year of age at injury, the relative risk of dying was increased by 8 percent (RR 1.08, 1.06; 1.09).^81^ Whether the reported increased risk of all CVD in tetraplegic compared to paraplegic individuals can be interpreted as an evidence of higher morbidity^53,^ ^76^ requires additional studies. Limited evidence suggests that cardiovascular mortality may contribute to approximately 20 percent of all deaths in SCI patients^1,^ ^36,^ ^49,^ ^52^ and coronary heart disease to 9 percent of all deaths.^1^–^3^ There is insufficient evidence to determine whether percentage of deaths due to CVD differs in SCI adults compared to appropriately matched able-bodied individuals. One study suggested that presence of heart diseases was associated with a 3.7 fold increased risk of death in SCI patients compared to SCI patients without CVD, independent of age and other risk factors.^52^ Limited evidence suggests that the contribution of different forms of heart disease (e.g., ischemic vs. nonischemic coronary heart disease) to overall CVD mortality in SCI patients may differ from the general population. However, proportionate mortality in SCI patients cannot give a valid estimation of mortality rates in this population. Standardized mortality ratios from nonischemic heart diseases, artery diseases, and lung emboli were higher in all injured adults compared to the general population.^2^ Mortality from lung emboli contributed the most to the overall differences within the total population. However, the inconsistency of results and the multiplicity of outcomes assessed makes it very plausible that these are chance findings.

Whether the independent contribution of diabetes and impaired glucose tolerance on CVD prevalence differs in adults with versus without SCI has not been reported. The association between metabolic control and CVD in adults with SCI remains unclear. Prevalence of retinopathy was not different in SCI users of the VA health care system who were diabetic compared to diabetic able-bodied veterans.^37^ The impact of lipid disorders on CVD in SCI individuals is not well documented and needs future investigation.

There is no evidence that diagnostic and treatment threshold for carbohydrate and lipid disorders should differ in SCI vs. able-bodied individuals. Assessment of insulin resistance and impaired glucose tolerance are not routinely performed in able-bodied individuals. The effectiveness of screening to improve clinical outcomes by detection of pre-diabetes (impaired fasting glucose or impaired glucose tolerance), insulin resistance, and diabetes in asymptomatic adults has not been demonstrated.^73^ Use of these tests is limited due to their inconvenience, complexity of testing requirements, costs, and current lack of accuracy. The OGTT is inconvenient and not ordered by most physicians to diagnose diabetes, even among those at risk. Additionally, about one-half with IGT or OGTT would have normal tests if repeated. Similar concerns exist with the criteria used to define impaired fasting glucose. Because the glucose concentration distribution is unimodal, the choice of cutpoints used to designate abnormalities of carbohydrate metabolism is arbitrary. A recent systematic review assessed the comparative effectiveness and safety of oral medications for Type 2 diabetes mellitus. The authors reported that there was no definitive evidence about the comparative effectiveness of oral diabetes agents on all-cause mortality, cardiovascular mortality, or morbidity, peripheral arterial disease, neuropathy, retinopathy, or nephropathy.^82^ Two more recent meta-analyses of thiazolidinediones have been conducted. Among able-bodied patients with impaired glucose tolerance or Type 2 diabetes (n=14,291), rosiglitazone use for at least 12 months was associated with an increased risk of myocardial infarction and heart failure. There was no difference in increased risk in cardiovascular mortality.^83^ A review of pioglitazone (n=16,390) showed a significantly lower risk of death, myocardial infarction, or stroke among patients with Type 2 diabetes and inadequate glycemic control. Serious heart failure was increased.^84^ Existing recommendations to assess cardiovascular risk for able-bodied individuals suggest that all adults should have a complete lipid profile, including HDL and LDL cholesterol levels, as well as family history, smoking status, and gender. The treatment recommendations should be based on that comprehensive risk assessment. Future studies are needed to determine if SCI should be included as an independent risk factor.

The evidence that exercise programs alter carbohydrate and lipid outcomes is of poor quality and inconclusive. Only one study examined the effects of exercise on coronary heart disease outcomes or survival, with no identified associations. There were relatively few consistent findings pertaining to plasma glucose, two-hour post-load glucose, fasting insulin, or two-hour post-load insulin. Similarly, little consistency was reported between studies for HDL cholesterol, TC/HDL, and TG. Results may have indicated some overall post-training benefits for outcomes of TC and LDL cholesterol. While many reported findings are suggested as beneficial in the primary papers as well as past reviews,^85^ caution in warranted. There was a general lack of quantity, quality, and consistency in methods and outcomes across studies. Reports were based on short-term exercise protocols, often involved carefully recruited hospital- and/or clinic-based patients, and failed to consider implementation or sustainability of exercise interventions in community-based populations. The exercise described in these papers varied considerably from one study to the next. In the cross-sectional surveys, parameters of physical activity were rarely reported.

Exercise and dietary programs among able-bodied individuals have demonstrated a modest improvement in carbohydrate and lipid parameters among selected highly motivated individuals. Translation of these findings to community settings of SCI adults has not been demonstrated and even the effectiveness in the general able-bodied population is unclear. For example, a recent randomized trial evaluated the effects of 22 weeks of aerobic training, resistance training, or both (three times per week) on glycemic control in 251 able-bodied adults with Type 2 diabetes.^86^ Combined training resulted in a 1 percent absolute reduction in glycated hemoglobin values versus sedentary controls. Reductions due to either resistance or aerobic training alone were about one-half that seen with combination therapy. There was no difference in lipid values, blood pressure, lean body mass, fat mass, or percent body fat of any of the exercise programs versus controls. Adverse events were more common in the exercise group, and 14 percent of those randomized to exercise dropped out.

## Conclusions

The available evidence regarding the prevalence, impact, and outcomes of carbohydrate and lipid disorders in adults with chronic SCI is weak. Evidence is limited by relatively small sample size, lack of appropriate control groups, failure to adjust for known confounding variables, and variation in reported outcomes. However, the existing evidence does not indicate that adults with SCI are at markedly greater risk for carbohydrate and lipid disorders or subsequent cardiovascular sequelae than able-bodied adults. The available evidence does not support incorporating SCI status as an independent variable to assess risk of cardiovascular morbidity and mortality or to alter diagnostic/treatment thresholds compared to able-bodied adults. Individuals with SCI may have unique physiologic differences compared to able-bodied individuals. Therefore, caution is advised in attempting to extrapolate findings from studies conducted in able-bodied adults evaluating efficacy and harms of interventions to improve carbohydrate, lipid disorders, and subsequent CVD. Assessment of obesity and body composition by BMI is likely inaccurate and underestimate risks. Alternative methods for assessment in SCI populations are needed. However, unless future high-quality studies suggest otherwise, current evidence supports the conclusion that detection and treatment of carbohydrate and lipid disorders in adults with SCI should be similar to able-bodied individuals.

## Future Research

A major gap in the evidence is the lack of high-quality prospective epidemiologic studies assessing the prevalence and impact of lipid and carbohydrate abnormalities and corresponding CVD complications in SCI individuals, especially compared to appropriately matched able-bodied controls. Future research could include a large prospective multicenter cohort study of adults with SCI. Risk assessment should be started at the time of injury and continued during long-term followup. Prevalence and incidence assessment needs to be objective rather than self reported. Inclusion of baseline and followup physiologic and serologic values (e.g. body composition measures, actual lipid and carbohydrate laboratory values) and standardized outcomes should be made according to well-recognized diagnostic criteria of heart diseases. Expansion of existing cohort studies in the VA, a large non-VA cohort study, and future RCTs that aim to test whether more aggressive screening or treatment within SCI populations actually reduces disease prevalence, morbidity, and mortality could be initiated. Additional information on women is needed.

If prospective cohort studies identify an increased risk in adults with SCI, RCTs will be needed to further extend the information. Techniques for identifying and treating these carbohydrate and lipid disorders and CVDs may need to be modified to meet the specific needs of those with SCI.

The level of injury, neurological impairment, and other known or potential confounders including smoking status, hypertension, family history, race, age, diabetes, infections, socioeconomic status, and quality of health care should be analyzed as possible effect modifiers of the association between well known risk factors and cardiovascular morbidity and mortality.

Consistent, higher quality research on exercise and metabolic and cardiovascular health in SCI patients is needed. Studies examining effectiveness as well as efficacy of exercise interventions are needed. Continued research should be conducted to gain a better idea of the important barriers to exercise experienced by individuals with SCI and to develop novel methods to overcome these barriers. Preliminary studies may also assess which patients are most in need of intervention, the best types of exercise programs and equipment, and how to modify them based on characteristics of the injury. Whether qualitative or quantitative, this preliminary work would not only inform the development of exercise programs but also the research used to evaluate efficacy and effectiveness.

Short-term, intermediate outcomes of exercise, as were typically reported in the current studies, may not be ideal or definitive measurements for this type of research. Studies ideally would focus on long-term clinically relevant outcomes such as prevention of or improvement in diabetes mellitus, coronary heart disease, and mortality. Long-term harms and adherence also need to be assessed. Key variables to be included in future studies are age, race, and gender; comorbid conditions; baseline lipid and carbohydrate related measures; duration, level, and completeness of SCI; functional status; baseline physical activity; exercise program type, frequency, intensity, and duration; and life satisfaction and other important psychosocial variables.

An RCT would provide the best evidence for or against the use of exercise to prevent or control carbohydrate and lipid disorders among those with SCI, though conducting adequately sized studies would be difficult and require cooperative group participation. Further research will be needed to translate any findings of exercise efficacy into effective community-based interventions. Even if efficacy is promising, it will remain to be seen if these interventions are feasible in a community setting and if the interventions, as well as health outcomes, are sustainable over time. Further evidence on how best to motivate individuals to sustain exercise, while preventing and identifying potential harms, will be needed.

RCTs evaluating the potential effectiveness and harms of pharmacologic and dietary interventions to alter CVD risk factors (diabetes, lipid abnormalities and/or obesity) and reduce CVD incidence, morbidity, and mortality may be needed if there is continued concern that results may differ in SCI populations compared to able-bodied adults.