# Acknowledgments

We would like to thank Yuying Chen, M.D., Ph.D., James Fitzsimmons, M.D., David Gater, M.D., Leonard Pogach, M.D., Suparna Rajan, Ph.D., and Thomas E. Stripling for helpful advice throughout the review process, for reviewing the draft, and providing recommendations for revisions and clarifications, and James H. Rimmer, M.D., and William A. Bauman, M.D., for reviewing the draft and providing recommendations for revisions and clarifications. We would also like to thank Maureen Carlyle for assistance with figures and Marilyn Eells for editing and formatting this report.