# Discussion

## Prevalence and Risk Estimates

The present systematic review evaluated published evidence regarding the prevalence of lipid and carbohydrate disorders, CVDs, and mortality in adults with chronic posttraumatic SCI. We attempted to assess the contribution of risk of these disorders to CVD morbidity and mortality and whether they vary according to SCI status or compared to able-bodied individuals. The potential efficacy and harms of interventions to improve carbohydrate and lipid disorders in this population was also examined. This information was synthesized to determine if compared to able-bodied adults individuals with SCI:

1 have a different prevalence of carbohydrate disorders;
2 have increased risk of CVD morbidity and mortality,
3 have CVD and/or carbohydrate/lipid benefits from specific interventions;
4 should have thresholds/methods for detection or treatment modified.

The level of evidence addressing these issues is low. Most studies were retrospective, small, lacked adequate controls, and did not assess or adjust for confounding factors. Outcome measure definitions varied widely. However, limited low quality data suggest that adults with SCI are not at markedly higher risk of carbohydrate and lipid disorders or CVD than appropriately matched able-bodied individuals. Except for assessment of body composition/obesity, evidence does not support that diagnostic and treatment thresholds or methods for carbohydrate and lipid disorders should differ in SCI compared to able-bodied individuals. Assessment of insulin resistance and impaired glucose tolerance are not routinely performed in able-bodied individuals. The effectiveness of screening to improve clinical outcomes by detection of pre-diabetes (impaired fasting glucose or impaired glucose tolerance), insulin resistance, and diabetes in asymptomatic adults has not been demonstrated.^73^ Use of these tests is limited due to their inconvenience, complexity of testing requirements, costs, and current lack of accuracy. The OGTT is inconvenient and not ordered by most physicians to diagnose diabetes, even among those at risk. Additionally, about one-half with IGT or OGTT would have normal tests if repeated. Similar concerns exist with the criteria used to define impaired fasting glucose. Because the glucose concentration distribution is unimodal, the choice of cutpoints used to designate abnormalities of carbohydrate metabolism is arbitrary. Very little high quality data exist on the independent role of gender, race, disease severity, level, or duration. Any observed differences in prevalence or risk is relatively small in magnitude, inconsistent in direction according to study or risk characteristic, and/or could be confounded by differences in other known risk factors: age, smoking, exercise status, family history, etc.).

Assessment of obesity using BMI, is likely to be inaccurate and underestimate body fat assessment in adults with SCI. For other measures of carbohydrate and lipid abnormalities there is no high quality evidence to indicate that different thresholds (or biomarkers) should exist for SCI individuals compared to able-bodied adults to identify patient risk level, define disease status, or initiate treatment. Little data exist on the effects of interventions to improve carbohydrate and lipid abnormalities, including the effect of exercise.

Several previous reports and reviews have suggested that the prevalence of carbohydrate and lipid disorders, as well as cardiovascular morbidity and mortality, is much higher in adults with SCI compared to able-bodied individuals. However, the prevalence of insulin resistance, metabolic syndrome, diabetes mellitus, impaired glucose tolerance, dyslipidemia, and obesity in a population is highly dependent upon demographics of the population, including most importantly the age distribution, but also socioeconomic status and race/ethnicity. The dependence of these conditions on population characteristics makes it difficult to make between study comparisons, since the population characteristics vary greatly both between and within studies. These factors may explain the wide variation in study prevalence estimates as well as the relative risk compared to different able-bodied control populations. Additionally, definitions of disease or condition may also alter prevalence estimates. In the one included study assessing metabolic syndrome, the definitions used by the authors for hypertension, obesity, diabetes, and lipid disorders are not widely accepted or utilized in studies in able-bodied adults. Their definitions increase the estimated prevalence of disease in their population and relative to studies of able-bodied individuals that use established definitions.

Our findings of cardiovascular disease prevalence and mortality were lower than frequently reported. Previous reviews often incorporated a broad definition of CVD.^76^ Definitions included in these reports were hypertension, as well as self-reported signs and symptoms of leg swelling or palpitations.^56^ The clinical significance and the relation to CVD of leg swelling and palpitations are not clear. Accurate assessment of blood pressure in SCI individuals is problematic. No validated definitions or thresholds for hypertension interventions exist in SCI patients due to blood pressure measurement issues related to autonomic dysreflexia, muscle spasticity or hypotonicity, use of arms for wheelchair transportation, and, most importantly, the lack of long-term data correlating blood pressure and treatment with morbidity and mortality in SCI individuals. These highly prevalent conditions are much more common and inflate prevalence estimates of cardiovascular disease in SCI individuals but result in less morbidity than myocardial infarction or stroke. Use of self-reported disease classification or death certificates for cause of death may also result in biased estimates of disease prevalence or mortality. Several factors may contribute to the increased prevalence of undiagnosed CVD in SCI individuals, including access and quality of care, asymptomatic angina in patients with diabetes or upper level injury,^77,^ ^78^ and metabolic syndrome, unstable blood pressure, and cardiac rhythm.^79,^ ^80^ Screening to detect asymptomatic heart diseases, including coronary heart disease, arrhythmias, and autonomic dysreflexia, may result in higher prevalence of CVD in this population.

Prevalence of CVD in aging SCI individuals can be attributable to age rather than injury. Patients differed by the prevalence of risk factors prior to injury and by age at the time of injury, both could modify the association between SCI and CVD. Indeed, recently published retrospective analysis found that presence of cardiovascular disease prior to injury was associated with a 280 percent increase in risk of death (relative risk 2.8, 95 percent CI 1.22; 6.40).^81^ For each additional year of age at injury, the relative risk of dying was increased by 8 percent (RR 1.08, 95 percent CI 1.06; 1.09).^81^

Whether the reported increased risk of all CVD in tetraplegic compared to paraplegic individuals can be interpreted as an evidence of higher morbidity^53,^ ^76^ requires additional studies. Limited evidence suggests that CVD may contribute to approximately 20 percent of all deaths in SCI patients^1,^ ^36,^ ^49,^ ^52^ and coronary heart disease in 9^1^–^3^ to 13^81^ percent of all deaths.^1^–^3,^ ^81^ There is insufficient evidence to determine whether percentage of deaths due to CVD differs in SCI adults compared to appropriately matched able-bodied individuals. One study suggested that presence of heart diseases was associated with an increased risk of death by 3.7 fold in SCI patients independent of age and other risk factors.^52^ Limited evidence suggests that the contribution of different forms of heart disease (e.g., ischemic versus nonischemic coronary heart disease) to overall CVD mortality in SCI patients may differ from the general population.

CVD morbidity and mortality in SCI patients showed inconsistent differences compared to the general population. Survival rates in aging injured patients can depend on severity of CVD and quality of care. Whether the incidence of CVD was not well documented in the studies or the prognosis of CVD is worse in the SCI than in the able-bodied population is unclear. Case fatality from CVD in SCI patients compared to the general populations is not well established. However, some evidence suggested that case fatality rate for pneumonia was higher in injured than in the general population.^109^

The independent contribution of diabetes and impaired glucose tolerance on CVD prevalence in adults with versus without SCI has not been reported. The association between metabolic control and CVD in adults with SCI remains unclear. Vascular complications were not different in SCI users of the VA health care system who were diabetic compared to diabetic able-bodied veterans.^37^ The role of lipid disorders on CVD in SCI individuals is not well documented and needs future investigation.

Some potentially eligible studies that may be cited as evidence of altered risk were excluded due to small sample size that limited generalizability (n=45, number of SCI individuals in each study ranged from 1–77). These studies were also of low quality and relevance because they were from a single center, not from the United States, lacked controls, and/or did not assess clinically relevant carbohydrate and lipid disorders. The impact of these studies on our overall findings regarding carbohydrate, lipid and body composition disorder prevalence, and subsequent clinical decision making is likely to be small. Only 17 excluded studies had control groups. The largest study reporting glucose intolerance and insulin resistance in the United States lacked controls, was comprised of 57 adults from a single center, and was published in 1983. The largest excluded controlled study of lipid disorders was a single center report comprised of 60 young SCI adults (mean age = 28 years) and 28 age and gender matched healthy able-bodied controls. Serum LDL cholesterol was higher (109 mg/dL vs. 91 mg/dL; p = 0.04) and HDL cholesterol lower (33 mg/dL vs. 44 mg/dL; p = 0.004) in SCI adults versus controls. The authors concluded that “serum lipoprotein levels should not be ignored for the followup of the patients with spinal cord injury.”^75^ We agree with their conclusion. Other excluded studies were of even lower quality and relevance to health care in the United States because they were smaller, from a single center, not from the United States, lacked controls, and/or did not assess clinically relevant carbohydrate and lipid disorders.

## Role of Exercise, Diet, and Pharmacologic Interventions

The evidence that exercise programs alter carbohydrate and lipid outcomes is of poor quality and inconclusive. There were relatively few consistent findings pertaining to plasma glucose, two-hour post-load glucose, fasting insulin, or two-hour post-load insulin. Similarly, little consistency was reported between studies for HDL-C, TC/HDL, and TG. Results may have indicated some overall post-training benefits for outcomes of TC and LDL-C. While many reported findings appear to be encouraging and are suggested as such in the primary papers as well as past reviews,^85,^ ^110^ caution is warranted when interpreting these studies. There was a general lack of quantity, quality, and consistency in methods and outcomes across studies. Overall, reports were based on short-term exercise protocols, often involved carefully recruited hospital- and/or clinic-based patients, and failed to consider implementation or sustainability of exercise interventions in community-based populations. Only one study examined the effects of exercise on coronary heart disease outcomes.^54^

The exercise described in these papers varied considerably from one study to the next. In the cross-sectional surveys,^13,^ ^14,^ ^54,^ ^69^–^71^ parameters of physical activity were rarely reported. Generally, questions pertaining to amount of physical activity per week were asked.^14,^ ^69^–^71^ In exercise intervention studies, little consistency in duration, mode, frequency, or intensity of the exercise programs existed. The length of the exercise protocols ranged from 8 to 52 weeks; most were only 8 to 16 weeks in duration.^57^–^61,^ ^64^–^67^ These studies may not have been long enough to impart measurable physiological benefits to study participants. Further, the types of exercise, frequency of sessions, and intensity of exertion were also varied, making results about preferred forms of exercise inconclusive.

Patient populations and outcome measures were also highly inconsistent. Study designs consisted only of case series, involving small numbers of subjects in hospital or clinical settings, or the cross-sectional surveys. The total number of subjects participating was low (n=101 for carbohydrate studies and n=292 for lipid studies) and, for the most part, subjects were not randomly selected from broader patient or community populations. These methods are considered highly susceptible to bias. Subjects that participated in the case series studies were likely a highly-motivated group of individuals, nonrepresentative of the broader population of those with SCI. Little information was presented on those asked to participate but who chose to abstain. Further, the measures of self-reported exercise or physical activity utilized in the cross-sectional surveys likely led to misclassification through recall error and social desirability issues. Even if measurement of physical activity was accurate, the cross-sectional nature of these surveys leaves results highly questionable due to possible confounding. For example, those who did not exercise may have had underlying carbohydrate and/or lipid metabolism disorders. This would make physical activity positively correlated, but not necessarily causally associated, with better carbohydrate and lipid measures.

None of the intervention studies used improvement in glycated hemoglobin (A1C) as an outcome. The effect of exercise on blood glucose often is delayed for several hours. A1C reflects the integrated effect on blood glucose throughout the day and A1C is easy to measure. Therefore, it would likely be preferable for future studies to track A1C changes rather than transient and more difficult to measure insulin or glucose levels or areas under the insulin and glucose curves for a few hours.

Even if consistent, convincing data were generated from these types of studies, there is no evidence for subsequent, successful translation of exercise interventions to a lesser motivated or community-based SCI population. Effectiveness of exercise interventions has yet to be studied in a population of individuals with SCI. Implementation and sustainability of exercise in this population is likely to be more challenging than in an able-bodied population, given the environmental barriers and physical risks, such as exercise-induced autonomic dysfunction and musculoskeletal injury.^8,^ ^26^ The risk of further, unperceived health problems, such as silent ischemia, in denervated subjects should be carefully considered prior to implementing exercise-related recommendations or policies.

Exercise and dietary programs among able-bodied individuals have demonstrated a modest improvement in carbohydrate and lipid parameters among selected highly motivated individuals. Translation of these findings to community settings of SCI adults has not been demonstrated, and even the effectiveness in the general able-bodied population is unclear. For example, a recent randomized trial evaluated the effects of 22 weeks of aerobic training, resistance training, or both (three times per week) on glycemic control in 251 able-bodied adults with Type 2 diabetes.^86^ Combined training resulted in a 1 percent absolute reduction in glycated hemoglobin values versus sedentary controls. Reductions due to either resistance or aerobic training alone were about one-half that seen with combination therapy. Their was no difference in lipid values, blood pressure, lean body mass, fat mass, or percent body fat of any of the exercise programs versus controls. Adverse events were more common in the exercise group, and 14 percent of those randomized to exercise dropped out.

Ultimately, higher-quality studies examining effects of exercise on the health of subjects with SCI need to be conducted. While carbohydrate and lipid metabolism measurements are important, intermediate measures, extending such studies into longer term outcomes such as diabetes mellitus, coronary heart disease, and survival are important. In addition, clinical and research questions pertaining to obesity in individuals with SCI remain to be answered. The most appropriate measurements and definition of obesity for those with SCI have not been identified at this time. To continue the use of BMI as a measurement of obesity, it must be assessed whether current BMI cutpoints for the general population can be extrapolated to those with SCI, or whether cutpoints need to be specific to this population, considering both SCI type and level.

Little information exists regarding the impact of dietary or pharmacologic interventions on adults with SCI. Recommendations currently exist for disease definitions for diabetes and lipid abnormalities in able-bodied adults. Several large RCTs have established the effectiveness of statins used for primary prevention in able-bodied adults with mean baseline LDL cholesterol of approximately 150 mg/dL. Many of these individuals had other competing risks such as hypertension and cigarette use. Use of statins in able-bodied adults with diabetes have been demonstrated to be effective even if baseline LDL-C is less than 130 mg/dL. The mean baseline LDL-C in populations of SCI individuals included in this review was 125 mg/dl. Effectiveness and harms associated with statins may differ in SCI individuals compared to able-bodied adults. However, unless contrary data exist, it seems reasonable to extrapolate these findings and recommendations for similar pharmacologic intervention thresholds for treatment of lipid abnormalities in SCI individuals as used in able-bodied adults. There have been no primary prevention studies among individuals with low HDL-C. Recent studies of treatments to raise HDL-C have been stopped due to harm. Existing recommendations to assess cardiovascular risk for able-bodied individuals suggest that all adults should have a complete lipid profile, including HDL and LDL cholesterol levels, as well as family history, smoking status, and gender. The treatment recommendations should be based on that comprehensive risk assessment. Future studies are needed to determine if SCI should be included as an independent risk factor.

With regard to interventions to prevent and treat diabetes, currently no large scale randomized trials have demonstrated that aggressive control of Type 2 diabetes reduces cardiovascular complications. A recent systematic review assessed the comparative effectiveness and safety of oral medications for Type 2 diabetes mellitus. The authors reported that there was no definitive evidence about the comparative effectiveness of oral diabetes agents on all-cause mortality, cardiovascular mortality or morbidity, peripheral arterial disease, neuropathy, retinopathy, or nephropathy.^82^ Two more recent meta-analyses of thiazolidinediones have been conducted. Among able-bodied patients with impaired glucose tolerance or Type 2 diabetes (n=14,291), rosiglitazone use for at least 12 months was associated with an increased risk of myocardial infarction and heart failure. There was no difference in increase risk in cardiovascular mortality.^83^ A review of pioglitazone (n=16,390) showed a significantly lower risk of death myocardial infarction or stroke among patients with Type 2 diabetes and inadequately glycemic control. Serious heart failure was increased.^84^ Unless future RCTs demonstrate evidence to the contrary, a reasonable policy would be to implement existing diabetes detection and management guidelines used for able-bodied adults.

## Conclusions and Policy Implications

Available evidence regarding the prevalence, impact, and outcomes of carbohydrate and lipid disorders in adults with chronic SCI is weak. Evidence is limited by relatively few studies, small sample size, lack of appropriate control groups, failure to adjust for known confounding variables, and variation in reported outcomes. However, the existing evidence does not indicate that adults with SCI are at markedly greater risk for carbohydrate and lipid disorders or subsequent cardiovascular sequelae than able-bodied adults. Cardiovascular diseases are among the leading causes of death in aging patients with chronic SCI. Therefore, patients with SCI should be assessed and treated according to existing guidelines for able-bodied individuals to reduce cardiac morbidity and mortality in this population associated with carbohydrate and lipid disorders.

BMI to assess obesity and body composition is likely inaccurate and underestimates fat mass in adults with SCI. Available evidence does not support establishing different thresholds to define and treat abnormal traditional lipid and carbohydrate measures or to utilize other markers (e.g., insulin sensitivity or impaired glucose tolerance) for SCI individuals compared to able-bodied adults. Because evidence is weak, it is not possible to conclude that an increased risk of these disorders and their subsequent cardiovascular sequelae do not exist or that use of alternative measures of abnormality may not someday be found beneficial.

Individuals with SCI may have unique physiologic differences compared to able-bodied individuals. Therefore, caution is advised in attempting to extrapolate findings from studies conducted in able-bodied adults evaluating efficacy and harms of interventions to improve carbohydrate, lipid disorders and subsequent coronary vascular disease.

If clinical uncertainty regarding carbohydrate and lipid disorder risks in adults with SCI and determining the most appropriate interventions remain high priority areas, then future high quality research is needed. Until that time, a reasonable policy would be to use similar criteria to identify and treat carbohydrate and lipid disorders (outside of body composition assessment) in adults with SCI as currently recommended for able-bodied adults. The role of exercise in SCI individuals also represents a unique challenge and requires further exploration into the benefits, risks, and potential implications of broader based exercise programs. This systematic review did not assess the diagnosis and treatment of hypertension in SCI individuals or the other potential benefits of diagnosis and management of SCI individuals, such as improved wound healing. Additional clinical and research activities are needed to address these issues.

## Future Research

A major gap in the evidence is the lack of high-quality prospective epidemiologic studies assessing the prevalence and impact of lipid and carbohydrate abnormalities and corresponding CVD complications in SCI individuals, especially compared to appropriately matched able-bodied controls. Future research could include a large prospective multicenter cohort study of adults with SCI. Risk assessment should be started at the time of injury and continued during long-term followup. Prevalence and incidence assessment needs to be objective rather than self reported. Inclusion of baseline and followup physiologic and serologic values (e.g., body composition measures, actual lipid and carbohydrate laboratory values) and standardized outcomes are made according to well-recognized diagnostic criteria of heart diseases. Expansion of existing cohort studies in the VA, a large non-VA cohort study, and future RCTs that aim to test whether more aggressive screening or treatment within SCI populations actually reduces disease prevalence, morbidity, and mortality could be initiated. Additional information on women is needed.

To a large extent, research within the VHA patient population has provided an important foundation to the current knowledge, particularly within the United States, regarding the prevalence of carbohydrate and lipid disorders and relevant considerations in persons with SCI. If there is continued concern that adults with chronic SCI have a different prevalence than adults without SCI, then future research would benefit from an expansion of the existing cohort studies in the VA, a large non-VA cohort study, and future RCTs that aim to test whether more aggressive screening or treatment within SCI populations actually reduces disease prevalence, morbidity, and mortality.

The VA administrative and clinical datasets and data from other large health care systems provide researchers with a wealth of information regarding the epidemiology of carbohydrate and lipid disorders with SCI patients. These datasets allow for rapid estimation of the magnitude of disease burden from carbohydrate and lipid disorders and can help to develop hypotheses about the role SCI may play in the development of disease. However, administrative datasets often suffer from selection bias in terms of the persons included and the measurements obtained. Therefore, such datasets need to be enriched with prospective cohort style data collection. This can be accomplished by designing a registry of adults with SCI and collecting a baseline battery of key measurements on all persons. This comprehensive set of baseline measurements can then be combined with standard outcomes data collected in these healthcare settings to provide a detailed description of the natural history and etiology of various diseases.

While in many ways the VHA provides an ideal U.S. setting to obtain important information on persons with SCI, it must be accompanied by complementary research on representative SCI persons from health systems outside of the VA. This is particularly important, since women are currently underrepresented in VHA datasets, and veterans have often been found to have more competing comorbidities than nonveteran populations,^37^ which can make generalizations difficult without complementary non-VA data. Additionally, current reports indicate that approximately 90 percent of SCI subjects were men. It is not known if this is representative of the U.S. SCI population or only those reporting this information.

RCTs will be needed to further extend the information obtained from future prospective observational studies. Regardless of whether or not future trials indicate that individuals with SCI are at an increased risk of carbohydrate and/or lipid disorders, it is clear that, like the general population, a significant number of SCI individuals do have carbohydrate and lipid disorders and techniques for treating these disorders may need to be modified to meet the specific needs of those with SCI to ensure that they are being most appropriately treated. RCTs will therefore be needed to compare the effectiveness of any such modifications in treatment technique and intensity, including the same pharmacological agents recommended for the general population and specific for SCI patients' treatment options that would target impaired glucose tolerance and insulin sensitivity.

If prospective cohort studies identify an increased risk in adults with SCI, RCTs will be needed to further extend the information. Techniques for identifying and treating these carbohydrate and lipid disorders and CVDs may need to be modified to meet the specific needs of those with SCI. In addition, continued clinical and research questions pertaining to obesity in individuals with SCI remain to be answered. These include identification of the most appropriate measurements and definition of obesity for those with SCI, and whether current BMI cutpoints for the general population can be validly extrapolated to those with SCI.

RCTs evaluating the potential effectiveness and harms of interventions to alter CVD risk factors and reduce CVD incidence, morbidity, and mortality are needed. The level of injury, neurological impairment, and other known or potential confounders including smoking status, hypertension, family history, race, age, diabetes, infections including, socioeconomic status, and quality of health care should be analyzed as possible effect modifiers of the association between well-known risk factors and cardiovascular morbidity and mortality.

Given the variation in design across studies, the lack of consistent findings in this review was not surprising. While improved studies will be challenging due to limited resources, complicated study questions, a relatively small subject population, and invasive intervention, policy recommendations cannot be generated until higher quality evidence is available. Consistent, higher quality research on exercise and metabolic and cardiovascular health in SCI patients is needed. Studies examining efficacy as well as effectiveness of exercise interventions are needed.

Continued research should be conducted to gain a better idea of the important barriers to exercise experienced by individuals with SCI and to develop novel methods to overcome these barriers. Preliminary studies may also assess which patients are most in need of intervention, the best types of exercise programs and equipment, and how to modify them based on characteristics of the injury. For example, telemedicine approaches to home-based exercise programs could potentially help overcome barriers to accessing traditional facilities or equipment. Whether qualitative or quantitative, this preliminary work would not only inform the development of exercise programs but also the research used to evaluate efficacy and effectiveness.

Accomplishing the level of research needed will likely require a collaboration of researchers across sites. Convening a consortium of experts is a practical first step. Cooperative research groups could determine the most appropriate and pragmatic study parameters, including intervention type and outcome measures, and could propose the most feasible quality studies. RCTs and prospective epidemiologic studies for individuals with SCI could both contribute enhanced knowledge to the current evidence base. While such studies are resource intensive, these accomplishments could perhaps be better achieved through the pooling of resources, either by funding agencies, or by researchers through multiple site collaborations. The VA medical system, the SCI model systems sites, or the National SCI Statistical Center at the University of Alabama Birmingham may be poised to lead such multi-site collaboration and studies.

Short-term, intermediate outcomes of exercise, as were typically reported in the current studies, may not be ideal or definitive measurements for this type of research. Studies ideally would focus on long-term clinically relevant outcomes such as prevention of diabetes mellitus, coronary heart disease, and mortality.

An RCT would provide the best evidence for or against the use of exercise to prevent or control carbohydrate and lipid disorders among those with SCI, though conducting adequately sized studies would be difficult and would require cooperative group participation. Studies on exercise and metabolic and cardiovascular outcomes in the SCI population will be more definitive if important demographic and injury parameters are considered. Key variables that should be included in future studies are patient age, race, and gender; comorbid conditions; baseline lipid and carbohydrate related measures; duration, level, and completeness of SCI; functional status; baseline physical activity; exercise program type, frequency, intensity, and duration; and life satisfaction and other important psychosocial variables. RCTs and prospective epidemiologic studies with adequate numbers of participants should provide the least confounded evidence for or against exercise programs if the intervention and control groups are appropriately balanced and/or stratified by these variables.

Further research will be needed to translate any findings of exercise efficacy into effective community-based interventions. Even if efficacy is promising, it will remain to be seen if these interventions are feasible in a community setting, and if the interventions, as well as health outcomes, are sustainable over time. Further evidence on how best to motivate individuals to sustain exercise, while preventing and identifying potential harms, will be needed.

RCTs evaluating the potential effectiveness and harms of pharmacologic and dietary interventions to alter CVD risk factors (diabetes, lipid abnormalities, and/or obesity) and reduce CVD incidence, morbidity, and mortality may be needed if there is continued concern that results may differ in SCI populations compared to able-bodied adults.