# Results

## Study Identification

Figures 2–4 trace the flow of our literature search. Excluded studies are listed in Appendix D.

Figure 3. Flow chart for Question 2 references

Figure 2. Flow chart for Question 1 references

Figure 4. Flow chart for Question 3a references (exercise/physical activity interventions)

For Question 1, the 210 citations identified through the search were screened for inclusion. Exclusions were based on the following reasons: not human subjects (three articles), duplicate citation listings (six articles), review articles with no data of interest (six articles), not English language (19 articles), studies with less than 100 subjects (45 articles), not adult chronic SCI patients (50 articles), and no relevant data (58 articles). The remaining 22 articles meeting the inclusion criteria contained data for one or more of the following: metabolic syndrome or insulin resistance (one article), glucose intolerance or Type 2 diabetes (12 articles), lipid values (six articles), or obesity (nine articles) (Appendix E Table 1). Abstracts of the 45 identified studies that were excluded primarily for small sample size (i.e. they contained less than 100 SCI subjects if lacking controls or less than 100 total subjects if including controls) were further reviewed to determine the potential impact on our results and conclusions. The impact of these studies on our overall findings regarding carbohydrate, lipid and body composition disorder prevalence, and subsequent clinical decisionmaking is likely to be small. The number of SCI individuals in the excluded studies ranged from one to 77. Only 17 had control groups. The largest study reporting glucose intolerance and insulin resistance in the United States lacked controls, was comprised of 57 adults from a single center, and was published in 1983. The largest excluded controlled study of lipid disorders was a single center report comprised of 60 young SCI adults (mean age = 28 years) and 28 healthy able-bodied controls matched by age and gender. Serum LD cholesterol was higher (109 mg/dL vs. 91 mg/dL; p = 0.04) and HDL cholesterol lower (33 mg/dL vs. 44 mg/dL; p = 0.004) in SCI adults versus controls. The authors concluded that “serum lipoprotein levels should not be ignored for the followup of the patients with spinal cord injury.”^75^ We agree with their conclusion. Other excluded studies were of even lower quality and relevance to health care in the United States because they were smaller, from a single center, not from the United States, lacked controls, and/or did not assess clinically relevant carbohydrate and lipid disorders.

For Question 2, the library included 260 references after the deletion of duplicates; 18 references were found with a manual search of the citation lists; 243 were identified in MEDLINE^®^. We excluded 241 references for the following reasons: one review, one legal case, one news, two case reports, one case control study with <50 SCI patients, 16 case series with <50 patients, four evaluated events after diet, acupuncture, surgery, or drug therapy, 111 (46 percent) did not report cardiovascular events, and 104 (43 percent) examined patients with acute traumatic or not traumatic injuries. We reviewed 20 articles of the 19 studies that reported cardiovascular events in adults more than 1 year after traumatic SCI (Appendix E Table 2). Observational studies were conducted in the United States,^2,^ ^3,^ ^34,^ ^36,^ ^37,^ ^46^–^51^ United Kingdom,^52,^ ^53^ Canada,^54^ Denmark,^1^ Sweden,^55,^ ^56^ Australia,^39^ and Japan.^30,^ ^32^ Two publications reported different outcomes from the same Stockholm Spinal Cord Injury Study.^55,^ ^56^ The results from the Japanese National Livelihood Basic Survey were published twice and were considered as one study.^30,^ ^32^ Several American studies were conducted in the Veteran Affairs Spinal Cord Injury Services but differed by location, time, and outcome.^3,^ ^34,^ ^37,^ ^48,^ ^51^ One prospective cohort examined incidence of CVD in people with long-term SCI.^53^ Another prospective study evaluated mortality in patients with chronic SCI.^36^ One case control study compared probability of CVDs in patients with SCI compared to age-matched able-bodied persons.^46^ Retrospective cohorts evaluated prevalence of electrocardiogram (ECG) abnormalities,^34^ cardiovascular morbidity, and mortality in patients with chronic SCI^1^–^3,^ ^47,^ ^49,^ ^52^ compared to the general population^1,^ ^2,^ ^52^ and after adjustment for age, gender, level of injury, time after injury,^52^ race, etiology of injury, neurologic level of injury, American Spinal Injury Association Impairment Scale, ventilator dependency, sponsor of care, and autopsy.^49^ Cross-sectional surveys reported prevalence of diabetes after adjustment for age, race, marital status, duration of injury, employment and education,^37^ and prevalence of cardiovascular diseases after adjustment for age,^30,^ ^32^ gender, education, ethnicity, marital and vocational status,^50^ duration of cigarette use,^54^ duration of injury and functional status,^56^ and socioeconomic status of the patients.^55^

For Question 3, based on the criteria identified above, 304 citations identified through the keyword search were reduced to 19 for use as evidence. Exclusions were based on the following: 38 due to lack of adult, chronic SCI patient population; 18 due to lack of exercise program or measure of self-reported physical activity; 231 due to lack of relevant carbohydrate or lipid related outcome measures. Upon review of citations from the 18 eligible references and one previous review paper, one additional reference was identified and added to the evidence base.^69^ Thus, results of 19 original studies were synthesized to address this question.

For Question 3b, only two prospective studies in adults with SCI evaluated dietary and/or lifestyle interventions to reduce lipid levels and met inclusion criteria.^20,^ ^72^

## Outcomes

### Question 1

#### Overall Description

The prevalence of insulin resistance syndrome, metabolic syndrome, diabetes mellitus Type 2, impaired glucose tolerance, dyslipidemia, and obesity in a population are all highly dependent upon demographics of the population, including most importantly the age distribution, but also factors such as socioeconomic status and race/ethnicity. The dependence of these conditions on population characteristics makes it difficult to conduct between-study comparisons, since the population characteristics range greatly both between and within studies. For example, one study might include men and women between the ages of 18 and 70, and within such a study one would expect age and gender stratified proportions of Type 2 diabetes to vary several fold; however, studies of this sort might only present an overall percent that are diabetic. Such an overall value is difficult to interpret and nearly meaningless unless the study has an appropriate control group. In the included evidence tables and figures, results have been presented stratified by age and other key factors (including severity or duration of injury) when such information was reported, but the paucity of consistently stratified results makes pooled estimates nearly impossible. Therefore, we have chosen to focus primarily on the higher quality studies (largest observational reports with control groups).

#### Hyperinsulinemia (insulin resistance/metabolic syndrome)

Little is known regarding the extent to which hyperinsulinemia is related to SCI. Only one relatively small observational study reported results for metabolic syndrome and insulin resistance syndrome (Appendix E Table 1).^15^ This study included a convenience sample of 93 SCI subjects (mean age = 50 years) recruited from a single VA and local community clinics (86 percent male). Of these 93 subjects, 11 percent were insulin resistant when relying entirely on mean fasting glucose and insulin values; however, when glucose-regulating medications were taken into account, 22 percent of the subjects were insulin resistant.^15^ Metabolic syndrome was defined as the presence of three or more metabolic disorders, including hypertension (systolic blood pressure ≥130 mmg/Hg, diastolic pressure ≥85 mmg/Hg, or the use of antihypertensive medications), obesity (defined by waist circumference), hyperglycemia (fasting glucose ≥110 mg/Dl or presence of glucose-lowering medications), hypertriglyceridemia (fasting serum triglycerides ≥150 mg/dL or taking cholesterol-lowering medications), and low HDL cholesterol (<40 mg/dL). Using this definition, metabolic syndrome was noted in 22 percent. This study did not include a control group or attempt to present results stratified by age and gender or level and duration of injury. The authors definitions for specific metabolic disorders are not widely accepted and are likely to increase the estimated prevalence of a given disorder.^73^ A second study of 201 SCI patients included results from an oral glucose challenge and reported rates of hyperinsulinemia by type of SCI injury.^28^ This study found hyperinsulinemia in 53 percent of people with tetraplegia and 37 percent of paraplegics.

##### Summary

Currently, there are no high quality studies adequately assessing the prevalence of metabolic syndrome and insulin resistance syndrome in a large population of adults with SCI. There are also no data to assess if the prevalence of either metabolic syndrome or insulin resistance are elevated in adults with SCI compared to similar individuals without SCI. Since metabolic and insulin resistance rates are dependent on age, gender, and race/ethnicity, future studies are needed that are large enough to report rates stratified by these key factors.

#### Abnormalities in carbohydrate metabolism (diabetes mellitus and impaired glucose tolerance)

The prevalence of diabetes in SCI subjects has been reported in multiple studies (Appendix E Table 1).^3,^ ^15,^ ^28^–^37^ Several of these studies have also reported a comparison between SCI individuals and non-SCI subjects (Figure 5).^29,^ ^32,^ ^34,^ ^37^

Figure 5. Diabetes prevalence, SCI vs. Control

A total of 6,832 persons with SCI and 254,847 controls were included in the reviewed studies, of which the vast majority of all of SCI individuals came from two large Veterans Health Administration (VHA) studies.^34,^ ^37^ The largest of these studies included a national cross-sectional survey of 3,737 SCI adults who were users of the VA health care system, along with a control group of 6,413 non-SCI VA health-care user control subjects and data from the CDC Behavioral Risk Factor Surveillance System 2003 survey of 221,650 community-dwelling adults.^37^ This large study found a substantially greater portion of VA SCI individuals self reported that they had diabetes compared to the general population surveyed by the CDC (20 percent versus 7.6 percent, p<0.001). However, overall self-reported prevalence of diabetes in VA users with SCI was similar to the prevalence of diabetes in the non-SCI VA user population (20 percent vs. 21 percent). Another large study also from a VA population found similar rates of diabetes in SCI and non-SCI subjects (11 percent vs. 10 percent, respectively).^34^ Differences in the overall prevalence of diabetes between these two studies are likely due in part to differences in ascertainment of diabetes status (self-report versus diagnosis in administrative dataset) and differences in the ages of the subjects, with the study reporting higher veteran prevalence of diabetes including older subjects and self-reported surveys. Results from national representative able-bodied populations clearly show that the prevalence of diabetes is highly dependent on method of ascertainment or definition (diagnosed vs. undiagnosed diabetes vs. impaired fasting glucose (Figure 6). The two other studies that included non-SCI control groups reported increased diabetes prevalence among SCI individuals.^29,^ ^32^ Both of these studies found several-fold higher rates of diabetes among the SCI subjects but were published more than a decade earlier and had smaller sample sizes. The first of these studies also involved veterans with and without SCI from a single institution. This study had a small number of controls (n=50) and only three controls had diabetes.^29^ For this study diabetes was diagnosed using a one-time oral glucose tolerance test. There was some evidence that persons with SCI had higher scores on their oral glucose tolerance tests than would be expected based on their fasting plasma glucose levels compared to non-SCI controls. In the non-SCI control group, people who were categorized as diabetics had an average mean fast plasma glucose level of 115 mg/dl while mean levels for paraplegic and tetraplegic diabetics were 99 mg/dl and 102 mg/dl, respectively. The other study presented results from a survey of Japanese subjects with overall diabetes rates much lower than those observed in the U.S. population (the control group had a 1.2 percent prevalence of diabetes).^32^

Figure 6. Prevalence of diagnosed diabetes, undiagnosed diabetes, and impaired fasting glucose in men (NHANES 1999-2002)^102^

The relationship between increased age and increased diabetes prevalence in both able-bodied individuals and those with SCI is strong and clearly demonstrated in the large survey of SCI individuals by Lavela and colleagues^37^ and results from the nationally representative NHANES III study (Figure 6).^102^ However, we found no evidence to suggest that the association between age and diabetes was substantially different in SCI compared to non-SCI groups.

The prevalence of impaired glucose intolerance (IGT) has been studied less frequently. In the three studies that met our inclusion criteria,^28,^ ^29,^ ^31^ only one study included a non-SCI control group (n=50) (Appendix E Table 1).^29^ All three studies were of veterans receiving care at a VA hospital, and all reported approximately 30 percent SCI patients with IGT, while only 12 percent of controls had IGT. The fact that only six control individuals with IGT were included in the one study with a non-SCI control group makes it impossible to determine from these data whether IGT is increased or not.

##### Summary

The prevalence of diabetes appeared higher on average in SCI populations studied as compared to the general population. However, there is considerable reason to believe that the general population groups used were not appropriate controls for SCI patients. For example, lifestyle and comorbidities, irrespective of SCI, could be quite different. Therefore, the extent to which this increased the prevalence of diabetes is due to a causal relationship between the SCI and the development of subsequent diabetes is not well known. Overall, the VA patient control groups tended to be similar to the VA SCI patient populations in their rate of diabetes, and it was only when the rate of diabetes in the VA SCI patients was compared to the general public that the SCI individuals appeared to be at higher risk. Users of the VA health care system have greater comorbidities than either veterans not actively using the VA health care system or non-VA populations. Therefore, current evidence is insufficient to determine to what extent the higher rate of diabetes is independently attributable to SCI or to other factors that might be higher in adults who subsequently have a SCI than in the general public. While there was not consistent evidence that fasting plasma glucose was substantially different in SCI patients, some evidence suggests that these individuals may be more likely to meet IGT or diabetes mellitus diagnostic criteria following oral glucose tolerance tests. More research is needed to determine whether using the oral glucose tolerance test (OGTT) is more likely to diagnose diabetes in SCI compared to non-SCI patients, and whether individuals diagnosed with diabetes by OGTT benefit from treatment.

#### Abnormalities in lipid metabolism (hyperlipidemia and/or low HDL cholesterol)

Lipid disorders among SCI populations have been reported in seven included articles,^16,^ ^17,^ ^21,^ ^31,^ ^38,^ ^39,^ ^103^ of which three appear to have included SCI individuals from the same study.^16,^ ^17,^ ^40^ There appear to be a total of 1,413 SCI individuals in all of these studies. Three studies (n=747 SCI adults) included some form of a non-SCI control group (n=680 for controls assuming the Krum et al. 1992 study included a 1:1 match, even though the number of controls was not reported) (Appendix E Table 1 and Figure 7).^38,^ ^39,^ ^103^ The pooled results of the three studies with control groups (one study only reported total cholesterol) showed that on average individuals with SCI had lower TC, LDL cholesterol, HDL cholesterol, and TG. While these differences were statistically significant, none were likely to result in differences in clinical decisionmaking. All mean values were within less than a half a standard deviation. Furthermore, the mean 7.5 mg/dL lower (worse) value of HDL cholesterol among SCI individuals was counterbalanced by 11 mg/dL lower (better) LDL cholesterol and 10 mg/dL lower TG levels. When the mean lipid values from SCI individuals were compared to those of the able-bodied national male age norms for the NHANES study, the similarities between SCI and able-bodied lipid values were also observed (Figures 8–13). None of the mean lipid values were outside of the threshold established for primary prevention among able-bodied adults. Mean lipid values for SCI individuals were: total cholesterol (six studies) 194 mg/dL (range 188–205); LDL cholesterol (five studies) 125 mg/dL (range 120–126); HDL cholesterol (five studies) 42 mg/dL (range 39–46), and triglycerides (five studies) 122 mg/dL (range 108–148). Therefore in the absence of evidence that SCI status conveys an independent risk for coronary vascular events, detection and treatment strategies would be similar compared to able-bodied individuals.

Figure 9. Mean levels of LDL cholesterol, SCI studies

Figure 10. Mean levels of HDL cholesterol, SCI studies

Figure 11. Mean levels of triglycerides, SCI studies

Figure 12. Total cholesterol, LDL-C and triglyceride levels of able-bodied males by age (NHANES)

Figure 7. Weighted mean differences in lipid levels (mg/dL): Spinal cord injured subjects vs. controls

Figure 8. Mean levels of total cholesterol, SCI studies

Figure 13. HDL cholesterol levels of able-bodied males by age (NHANES)

The small number of SCI adults with reported lipid values makes it difficult to draw conclusions regarding subcategories of SCI adults with respect to age, sex, race/ethnicity, severity of SCI injury, and duration of SCI injury. The largest study of ethnicity and lipid levels in an SCI population included a total of 600 adults (percentage of whom were male was not reported) of whom 27 percent were White, 47 percent were Hispanic, and 27 percent were African American.^17^ While this study reported some racial/ethnic differences in lipid levels, there exists almost no evidence regarding whether these possible ethnic differences are unique to SCI individuals. Additionally, this study did not report whether the percentage of individuals who were male differed by ethnicity. The majority of SCI individuals in the studies were men, and even in studies that appeared to contain both men and women, the lipid values were not always reported by sex. In the few studies that did report female-specific lipid values,^21,^ ^39,^ ^40^ only two reported control groups (n=139 SCI women in controlled studies). Therefore, little evidence exists for whether women with SCI have different lipid levels than able-bodied women. With respect to the type of SCI injury (tetraplegia versus paraplegia, complete versus incomplete), the studies did not report a substantial difference in lipid levels.^16,^ ^31,^ ^38,^ ^40^

##### Summary

There is some evidence that on average SCI individuals may possess slightly, but likely not clinically meaningfully, reduced total cholesterol, LDL cholesterol, triglycerides (beneficial) and HDL cholesterol (detrimental). The evidence does not support a policy that lipid screening should differ in SCI adults compared to able-bodied adults.

#### Obesity

Reports in the general population have consistently shown that the level of obesity is increasing in the United States^104^ and that this increase in obesity is contributing to an excess in mortality.^105^ BMI is the primary method used for assessing obesity in population-based studies. However, several alternative methods for assessing obesity exist, including waist circumference, waist-to-hip ratio, percent body fat measured through multiple different techniques, percentage of ideal weight, and others. The use of general population cutpoints for obesity from BMI (>30 kg/m^2^) have been called into question by the finding that SCI individuals tend to have lower body fat at a given BMI as compared to non-SCI individuals.^42^ BMI has been and remains the predominant measure of obesity reported in SCI studies.

The prevalence of obesity among SCI populations has been reported in multiple studies,^28,^ ^31,^ ^36,^ ^38,^ ^40^–^45^ most of which have included some form of a non-SCI control group.^38,^ ^40,^ ^42,^ ^43,^ ^45^

A total of 10,226 persons with SCI (7,959 from one large VA clinical and administrative database study)^45^ and 246,478 control subjects (246,025 from one national population-based survey)^43^ contributed data to this section. Across these studies, mean BMI between SCI and non-SCI populations were relatively similar with non-SCI populations consistently having slightly elevated mean BMI (Figures 14 and 15). However, differences in mean BMI are difficult to interpret, not only because BMI might underestimate obesity in SCI individuals, but also because the relationship between BMI and disease is typically U- or J-shaped with those in the middle categories of BMI having the lowest risk compared to the lowest extreme and upper levels of BMI. Separating out the studies by category of BMI is therefore important. However, whether the category cutpoints for underweight, normal, overweight, and obese used in able-bodied populations can be applied to adults with SCI, is worthy of greater discussion and cannot be addressed based upon the available research. To date, many of the studies have either only reported mean BMI or merged underweight and normal weight categories together. Also, the extent to which the lower mean BMI findings in SCI populations compared to controls are due to an underestimate of obesity by BMI in individuals with SCI is difficult to address.

Figure 14. Mean BMI, SCI, and Control

Figure 15. Prevalence of BMI levels by age group (NHANES 1999-2002)^105^

Only one of the included studies directly assessed obesity by means other than algorithms based on weight and/or height, primarily recorded as BMI.^42^ This study of 133 SCI individuals and 100 age-, height-, and ethnicity-matched able-bodied male controls measured percent fat mass using dual energy x-ray absorptiometry (DXA). This study found that total percent lean mass was lower and total percent fat mass higher in SCI individuals for a given level of BMI. The findings from this study combined with the prior studies showing no striking difference in BMI between SCI and able-bodied populations would suggest that future studies should focus less on comparing BMI and should investigate whether other indicators of obesity are more relevant for this population and correspondingly more predictive of future adverse health events. However, it should be noted that while DXA is a reliable measure of body composition, it is also much more difficult and expensive to obtain than BMI.

Several studies have attempted to explore whether differences in injury type (paraplegia versus tetraplegia or complete versus incomplete) or injury duration are correlated with obesity, but as with the overall studies of obesity and SCI, these studies are mostly conducted only with BMI measurements of obesity. Studies that have looked at injury type have tended to find a slightly higher average BMI in adults with paraplegia versus tetraplegia.^28,^ ^38,^ ^42^–^45^ However, it is not clear from these studies the extent to which mean BMI is driven by more underweight individuals with tetraplegia or possibly a greater tendency for BMI to underreport obesity in people with tetraplegia compared to people with paraplegia.

Several clinical and research questions remain to be answered, including what is an appropriate definition for obesity in an SCI population? For example, can BMI be used to define obesity? If not, what should be used in its place? If so, can current general population cutpoints for BMI be used or does the cutpoint need to be different (i.e., either specific for SCI in general or even more specific for type of SCI injury)?

##### Summary

There is no high-quality evidence that obesity defined by BMI is elevated in SCI individuals compared to appropriately matched controls. While several authors have reported that BMI might not be an accurate measure of obesity in the SCI population, it is by far the predominant measure used in research studies of the prevalence of obesity. There is some evidence that when obesity is measured as percent body fat, SCI individuals may be at elevated risk; however, the absence of large studies that include accurate measurements of body fat preclude stronger conclusions from being made about the burden of obesity on individuals with SCI and the impact of injury type and duration on the extent of obesity.

### Question 2

#### Subject characteristics

The studies included more than 50,000 patients with SCI. Sample size ranged from 96^46^ to 28,239.^49^ Males (pooled prevalence 86 percent, 95 percent CI 80.4; 90.9) and Caucasians comprised the majority of individuals; all studies identified patients at clinics or administrative health care databases (Table 1 and Appendix E Table 2). Among American studies, large cohorts^2,^ ^49,^ ^50^ (studies that analyzed nationally representative databases, including the Centers for Disease Control and Prevention and the national Behavioral Risk Factor Surveillance System Survey),^37^ were considered to have higher generalizability. Applicability of several large studies from the VA Spinal Cord Injury Services can be generalized to veterans seeking care in the VA clinics and, to a lesser extent, general veterans with SCI or the overall adult SCI population.^3,^ ^34,^ ^37,^ ^48,^ ^51^ Individuals differed by the level of injury, the time after injury, and functional status, but few studies included these factors in the analysis. Several studies reported prevalence of hypertension,^3,^ ^30,^ ^32,^ ^34,^ ^37,^ ^39,^ ^48,^ ^51,^ ^53,^ ^55^ but only a few examined other risk factors of cardiovascular diseases, including smoking and lipid levels.^37,^ ^39,^ ^54^ Furthermore, definitions of these comorbidities and methods to measure (and therefore, likely prevalence) varied across studies. The majority of the studies obtained events with ICD codes (the conceptual definition of outcomes is shown in Appendix F). However, the studies reported the prevalence of the outcomes obtained with different ICD codes. For example, one study^53^ defined CVDs with ICD codes 390–448 and 745–747 that included rheumatic and hypertensive diseases as well as congenital anomalies of the heart while another^50^ defined outcome as rehospitalization for diseases of the circulatory system, including heart disease, hypertension, pulmonary embolus, cerebrovascular diseases, and disease of the arteries and veins. Therefore, definitive comparisons of outcomes were not possible. The accuracy and reliability of the coding in different settings could not be estimated from the published articles.

Table 1 Patient characteristics in studies that reported cardiovascular events in adults with SCI

Author | Sample | Patients
| Country
Cardus, 1992^46^ | 96 | Patients after traumatic SCI who resided in the county area and had to use assistive device for walking. Age: >18 years; Time after injury: >9 months. Controls: 96 nontrained able-bodied men matched by age.
| USA
Krum, 1992^39^ | 327 | Patients with SCI and age and sex matched controls from the 1983 Australian Risk Factor Prevalence Study. Gender: 19% female; 25–64 years old; Time after injury: 34% more than 10 years after injury; Injury: 40% with cervical, 35% with lower thoracic, 13% with upper thoracic, and 12% with lumbar levels of injury; ~41% with Frankel Grade A of completeness - complete motor and sensory deficit.
| Australia
Whiteneck, 1992^52^ | 834 | Patients with SCI, treated at the British spinal injury centers; Gender: 13% female; Age at time of injury was between 15 and 55 years—15–24 years 42%, 25–34 years 27%, 35–44 years 18%, 45–55 years; median survival time 32 years; Time after injury: >20 years; 412 survivors, Median survival time 32 years; 85% survived at 10 years, 71% at 20 years, 53% at 30 years, and 35% at 40 years after injury.
| UK
DeVivo, 1993^2^ | 9,135 | Patients injured between 1973 and 1984 and treated at any of 13 regional SCI care systems.
| USA
Imai, 1994^30^ | 244 | Males with SCI identified during the National Livelihood Basic Survey in Japan engaged in light work at special centers, who had medical examination for blood pressure and medical history. Mean age: 49.5 years; Time after injury: average 17.9 years; Injury: 19 patients injured at level C-T5, 24 at T6–T10, 139 at T11-L1, and 13 at L2 or lower.
| Japan
Nam, 1994^47^ | 1,027+2,007 | Patients admitted to medical centers with stroke and patients with traumatic SCI (paraplegia or quadriplegia). Population: average age 37.2±16.1 years.
| USA
Levi, 1995^55^ | 326 | Patients with traumatic SCI from the Stockholm Spinal Cord Injury Study, residents of the Greater Stockholm area. Control: participants in the Swedish Annual Level-of Living Survey (1,978 interviews).
| Sweden
Levi, 1995^56^ | 353 | Patients with traumatic SCI, participants in The Stockholm Spinal Cord Injury Study. Time after injury: 0–4 years after injury 23.97%; 5–17 years after injury 48.76%; 18–44 years after injury 24.52%.
| Sweden
McGlinchey-Berroth, 1995^48^ | 534 | Patients with traumatic SCI admitted to the high quality Spinal Cord Injury Service of the VA Medical Center; mean age of 50 years (16–84 years), 23% were at least 65 years of age; Gender: 99% males; Time after injury: 16±13.1 years, 12 hospital admissions since injury.
| USA
| VA settings
| Time: 1989-1992
Imai, 1996^32^(the same population as Imai, 1994)^30^ | 244, Japan | Males with traumatic SCI at several rehabilitation centers; ages 22 to 69 years (mean 47.6); Time after injury: 17.3 years; Injury: C-T5 level 1%; T6–T10 12%; T11-Ll 69%; L2 8%. Control group (general population) National Livelihood Basic Survey conducted by the Ministry of Health and Welfare in 1989, on 800,000 people in 240,000 households.
Hartkopp, 1997^1^ | 888 | Patients (713 men and 175 women) who survived traumatic SCI and were rehabilitated at the Centre for Spinal Cord Injured in Hornbnk, Denmark. Population: median age at the time of injury 27.5 in 1953-1971 and 28.5 in 1972-1990.
| Denmark
Rish, 1997^3^ | 230 | Patients with traumatic SCI identified in the Vietnam Head and Spinal Cord Injury Study Registry who survived more then 72 hours, with significant myelopathy; mean age at injury 21.4 years, with previous excellent health (active duty military personnel) mean age at injury 21.4 years; median time after injury 25 years.
| USA
| VA settings
| Time: 1967-1970 to 1995
DeVivo, 1999^49^ | 28,239 | Patients admitted to the model system or to a Shriner's Hospital within 1 year of traumatic SCI who survived at least 24 hours after injury; Gender: 19% female; Race: 67.6% Caucasian, 20.7% African American, 8.1% Hispanic, 3.6% Asian, Native American, or other; Time at injury: 54% of injuries occurred between the ages of 16 and 30 years, and 23% between 31 and 45 years; Injury: 53% cervical, C5–C8 34.5% and C1–C4 18.5% of the population; 53.8% neurologically complete, 27.2% motor functional, 19% sensory sparing or motor nonfunctional; 2.9% were ventilator-dependent.
| USA
Groah, 2001^53^ | 834 | Patients alive >20 years after SCI identified in 2 British spinal Injury centers; Mean age 57±10 years; Gender: 14% females; Time after injury: 29±6 years.
| UK
Davies, 2002^54^ | 97 | Patients with segmental, nonprogressive traumatic SCI; mean age 47.5±4.5; Gender: 10% females; Age at injury: 31.67±16.4; Time after injury: 15.9±10.1 years; Injury: Quadriplegic 42%; Paraplegic 57%; Undetermined 1%; Complete 33%; Incomplete 64%; Undetermined 3%; Traumatic 87%.
| Canada
Prakash, 2002^34^ | 654 | 47,070 patients with at least one ECG obtained in the Palo Alto Veterans Affairs Health Care System; 26,734 able-bodied male veterans and 654 patients with SCI. Mean age: 50±14 years.
| USA
| VA settings
| Time: 1987-1999
Cardenas, 2004^50^ | 8,668 | Patients with traumatic SCI identified in the Model System (hospitalized between acute hospitalization and comprehensive inpatient rehabilitation, admitted to a Model System within 365 days of injury) who reside in the geographic region in which the Model System facility is located; 3,904 patients with 11,047 followup interviews, Gender: 21.4% female; Race: 61.4% White
| USA | Injury: C1–4 ASIA grades A, B, C: 4.6%
| | C1–4 ASIA grade D: 6.1%
| | C5–8 ASIA grades A, B, C: 19.1%
| | C5–8 ASIA grade D: 8.5%
| | T1-S5 ASIA grades A, B, C: 33.1%
| | T1-S5 ASIA grade D: 4.2%
Lavela, 2006^37^ | 5,690 | Veterans with SCI and disorders who use VA health services; Mean age 60 years; Gender: 97% males; Race: White 81%; Time after injury: 24 years; Injury: 52% with paraplegic level injury. Control: 2003 Behavioral Risk Factor Surveillance System survey data for veteran and general population from the Centers for Disease Control and prevention. 6,433 general veteran group and 221,650 general population group.
| USA
| VA settings
| Time: 2003
Lee, 2006^51^ | 168 | Patients with SCI identified in the Spinal Cord Injury Service of the Veterans Affairs Palo Alto Medical Center; Mean age 50.27±12.8 years; Gender: 11% female; Race: 62% White; Time after injury: 19.17±13 years; Injury: 73 (43%) had paraplegia and 95 (56%) tetraplegia.
| USA
| VA settings
Garshick, 2005^36^ | 361 | Males with chronic SCI, >20 years of age previously treated by the SCI Service at Veterans Affairs Boston Healthcare System, registered in the National Spinal Cord Injury Association database in Massachusetts, New Hampshire, Vermont, Maine, and Rhode Island (289 veterans and 72 nonveterans); Mean age: 50.6±15.0 years (range 23–87), Race: 93% Caucasian, 5% African American, and 2% other races; Time after injury: 17.5±12.8 years (range 1.0–56.5); Injury: 92% SCI was due to traumatic injury; 37 deaths.
| USA
| VA settings
| Time: 1994-2000

#### Cardiovascular prevalence in adults with chronic SCI

Crude prevalence estimates were reported in the majority of the studies and ranged from 0.05 percent for cerebrovascular disease^53^ to 58 percent for self reported cardiovascular symptoms^56^ and differed, depending on how events were defined and measured (self reported or identified with ICD codes) and on age and time after SCI. Therefore, an overall summary estimate was not provided. The prevalence of cardiovascular diseases was <1 percent in two studies^32,^ ^50^ and 2 to 3 percent in three studies^52,^ ^53,^ ^55^ (Table 2). One smaller study of 140 patients used the London School of Hygiene Questionnaire on Chest Pain and Intermittent Claudication and reported a higher prevalence of CVDs (13.4 percent).^54^ One study found an increase in prevalence in older patients to 19.3 percent after 60 years of age at time of injury and to 14.2 percent 30 or more years after injury (Table 3).^52^ The prevalence of congestive heart failure was 2.7 percent in one study,^34^ and the prevalence of other cardiac diseases 2 percent^55^ or <2 percent.^53^ The prevalence of cerebrovascular diseases varied from <1 percent,^53^ to 1 percent^39^ or 2 percent.^3^ The prevalence of coronary heart disease was 2 percent or less in three studies,^32,^ ^39,^ ^53^ 6 percent among patients from the Vietnam Head and Spinal Cord Injury Study Registry,^3^ and the highest was 12 percent among members of Paralyzed Veterans of America.^37^ The Stockholm Spinal Cord Injury Study^56^ examined self reported prevalence of “cardiovascular symptoms” and included ankle-leg edema, chest pain, and palpitations. More than half of the patients with SCI reported symptoms (55 percent of males and 69 percent of injured females). However, prevalence of diagnosed cardiac diseases was only 2 percent. Whether this represents under diagnosis of cardiovascular diseases or classification of nonspecific symptoms which did not reflect CVD is not known. Seventy-two percent of patients with complete cervical and thoracic injury reported having cardiovascular symptoms. The prevalence of arterial hypertension was <3 percent in three studies,^30,^ ^32,^ ^53,^ ^55^ 5–10 percent in four studies,^30,^ ^34,^ ^39,^ ^48^ and more than 20 percent in four studies.^3,^ ^37,^ ^48,^ ^51^ The Vietnam Head and Spinal Cord Injury Study reported that 21 percent of the injured adults had hypertension^3^ and 25–49 percent of the patients of the Spinal Cord Injury Service of VA medical centers were diagnosed with arterial hypertension.^37,^ ^48,^ ^51^ In addition, borderline hypertension was found in 33 percent of the injured veterans.^51^ The prevalence of myocardial infarction was <5 percent in three studies.^3,^ ^39,^ ^53^

Table 2 Prevalence of CVD in adults with SCI

Author | Age, Years | Outcomes | Sample (n) | Prevalence, %
Garshick, 2005^36^ | Mean 50.6±15.0 | Hypertension | 361 | 24.4
Groah,* 2001^53^ | Mean 57±10 | Hypertension | 834 | 0.58
Krum, 1992^39^ | | Hypertension | 102 | 9
Lavela, 2006^37^ | Mean 60 | Hypertension | 18,372 | 49
Lee,* 2006^51^ | Mean 50.27±12.8 | Hypertension | 168 | 45.14
Levi, 1995^55^ | | Hypertension | 326 | 0
Prakash,* 2002^34^ | Mean 50±14 | Hypertension | 654 | 7
Rish,* 1997^3^ | Mean at injury 21.4, median time after injury 25 | Hypertension | 230 | 21
Imai, 1996^32^ | Mean 47.6 | Hypertension | 244 | 16.39
Imai, 1996^32^ | Mean 47.6 | Hypotension | 244 | 1.64
Lee,* 2006^51^ | Mean 50.27±12.8 | Prehypertension | 168 | 32.74
| | Stage 1 hypertension | 168 | 16.07
| | Stage 2 hypertension | 168 | 8.33
Krum, 1992^39^ | Range 25–64 | Cerebrovascular accident | 102 | 1
Rish,* 1997^3^ | Mean at injury 21.4, median time after injury 25 | Cerebrovascular accident | 230 | 2
Groah,* 2001^53^ | Mean 57±10 | Cerebrovascular diseases | 834 | 0.05
| | Angina | 834 | 0.07
Krum, 1992^39^ | Range 25–64 | Angina | 102 | 2
Prakash,* 2002^34^ | Mean 50±14 | Coronary artery disease | 654 | 1.7
Rish,* 1997^3^ | Mean at injury 21.4, median time after injury 25 | Coronary artery disease | 230 | 6
Groah,* 2001^53^ | Mean 57±10 | Coronary atherosclerosis | 834 | 0.27
Lavela, 2006^37^ | Mean 60 | Coronary heart disease | 18,372 | 12
Groah,* 2001^53^ | Mean 57±10 | Ischemic heart diseases | 834 | 0.65
Imai, 1996^32^ | Mean 47.6 | Ischemic heart diseases | 244 | 1.64
Groah,* 2001^53^ | Mean 57±10 | Myocardial infarction | 834 | 0.28
Krum, 1992^39^ | Range 25–64 | Myocardial infarction | 102 | 1.9
Lavela, 2006^37^ | Mean 60 | Myocardial infarction | 18,372 | 14
Rish,* 1997^3^ | Mean at injury 21.4, median time after injury 25 | Myocardial infarction | 230 | 3
Levi, 1995^55^ | | Cardiac diseases | 326 | 2
Davies, 2002^54^ | Mean 47.5±4.5 | Cardiovascular morbidity | 140 | 13.4
Groah,* 2001^53^ | Mean 57±10 | Cardiovascular morbidity | 834 | 2.72
Imai, 1996^32^ | Mean 47.6 | Circulatory diseases | 244 | 0.82
Levi, 1995^55^ | | Circulatory diseases | 326 | 2
Prakash,* 2002^34^ | Mean 50 ± 14 | Congestive heart failure | 654 | 1.7
Groah,* 2001^53^ | Mean 57±10 | Dysrhythmia | 834 | 0.43
| | Left bundle branch block | 834 | 0.02
| | Other CVD | 834 | 0.81
| | Valvular disease | 834 | 0.2
Levi, 1995^56^ | | Cardiovascular symptoms: ankle-leg edema, chest pain, palpitations | 353 | 58

* Outcomes events obtained with ICD codes

† Hospitalizations with CVD diagnosis

Table 3 Prevalence of CVD in adults with SCI by age and years after injury

Author | Sample (n) | Age at Injury | Prevalence, %
All CVD
Whiteneck, 1992*^52^ | 834 | <30 years | 2
| | 30–39 years | 2.9
| | 40–49 years | 5.2
| | 50–59 years | 8.1
| | 60+ years | 19.3
CVD symptoms
Levi, 1995^56^ | 162 | 21–40 years | 57
| | 41–77 years | 61
Hypertension
McGlinchey-Berroth, 1995*†^48^ | 255 | <50 years and <50 years at index submission | 5.09
| 162 | <50 years and >50 years at the time of index admission | 25.3
| 93 | Age at injury and index hospital admission >50 years | 33.33
Myocardial infarction
McGlinchey-Berroth, 1995†*^48^ | 255 | <50 years and <5 years at index submission | 5.09
| 162 | <50 years of age and >50 years at the time of index admission | 25.3
| 93 | >50 years of age | 33.33
| | Years after Injury
All CVD
Whiteneck, 1992*^52^ | 834 | <10 years | 2.9
| | 10–19 years | 5.4
| | 20–29 years | 10
| | 30+ years | 14.2
Cardenas, 2004*†^50^ | 3,978 | 1 year | 0.73
| 1,714 | 10 years | 0.41
| 1,653 | 15 years | 0.79
| 1,251 | 20 years | 0.4
| 2,451 | 5 years | 0.53
CVD symptoms
Levi, 1995^56^ | 87 | 0–4 years | 48
| 89 | 18–44 years | 72
| 177 | 5–17 years | 55

* Outcomes events obtained with ICD codes

† Hospitalizations with CVD diagnosis

SCI veterans had higher prevalence of myocardial infarction, 14 percent^37^ to 25 percent among those who were younger than 50 years at the time of injury and older than 50 years at the time of index admission to the Veterans hospital^48^ (Table 3). The highest prevalence of 33 percent was reported among veterans who were older than 50 years at the time of injury representing the effect of age rather than injury ^48^ Patients with tetraplegia and ABC functional status had lower age adjusted rates of coronary heart diseases, including myocardial infarction, and higher rates of cerebrovascular diseases, dysrhythmia, and valvular disease (Table 4) by neurologic category among 834 patients.^53^ Prevalence of cardiovascular symptoms and arterial hypertension appeared to vary by the level of injury, though statistical differences in rates were not provided (Appendix E Table 3).

Table 4 Prevalence of CVD* according to SCI neurological category^53^

Neurological Category | All SCI (N=834) | | Tetra ABC (N=99) | | Para ABC (N=285) | | All D (N=161)
| Number | Rate | Number | Rate | Number | Rate | Number | Rate
All CVD | 458 | 27.2 | 64 | 35.2 | 279 | 29.9 | 115 | 21.2
Coronary heart disease | 109 | 6.5 | 5 | 2.1 | 63 | 6.6 | 41 | 7.4
Myocardial infarction | 47 | 2.8 | 1 | 0.3 | 31 | 3.2 | 15 | 2.6
Angina | 12 | 0.7 | 0 | | 4 | 0.4 | 8 | 1.7
Coronary atherosclerosis | 46 | 2.7 | 3 | 1 | 25 | 2.7 | 18 | 3.1
LBBB | 4 | 0.2 | 1 | 0.3 | 3 | 0.3 | 0
Hypertension | 98 | 5.8 | 5 | 1.7 | 71 | 7.6 | 22 | 4.5
Cerebrovascular disease | 8 | 0.5 | 4 | 1.5 | 3 | 0.3 | 1 | 0.2
Dysrhythmia | 73 | 4.3 | 20 | 13.1 | 42 | 3.3 | 11 | 1.3
Valvular disease | 34 | 2 | 10 | 5 | 14 | 1.5 | 10 | 1.7
Other CVD | 136 | 8.1 | 20 | 9.2 | 86 | 1.4 | 30 | 1.5

* Age adjusted rates per 1,000 SCI person years by neurological category

##### Asymptomatic heart conditions in patients with SCI

Three studies reported cases of silent ischemia in asymptomatic adults with SCI.^10,^ ^106,^ ^107^ Tomographic thallium-201 myocardial perfusion imaging detected scintigraphic evidence of ischemia in 3 of 6 patients (50 percent) with tetraplegia and signs of infarction in one patient.^106^ A simple arm ergometry and radionuclide tomographic image test detected silent scintigraphic evidence of ischemia in 13 SCI patients with paraplegia from 20 tested having normal resting electrocardiograms (65 percent). Since five subjects had ECG evidence of ischemia on exercise testing, eight patients (62 percent) experienced undiagnosed coronary heart disease.^107^ Latent coronary artery was diagnosed in 12 of 19 subjects with paraplegia (63 percent) using radionuclide myocardial perfusion imaging after upper body ergometry exercise.^10^ A recently published case control study^108^ of coronary scanning showed that 91 patients with chronic SCI had the higher mean calcium scores (75±218 versus 28±104, p <0.001) compared to 273 age matched non-SCI controls. The prevalence of coronary artery calcification was greater in the SCI population than the control population (16 percent versus 7 percent, p <0.01).

Pooled analysis detected a significant heterogeneity between studies in estimated prevalence of cardiovascular diseases (data not shown). Therefore, methodological heterogeneity made the pooled estimations not valid. Almost all variations in pooled prevalence of hypertension (14 percent) and myocardial infarction (8 percent) were attributable to heterogeneity between studies. The fact that the summarized prevalence of all CVD events, including coronary heart and non ischemic heart diseases, was less than different forms of CVDs reported in the studies. Such discrepancy can reflect overlap and different definitions and methods to measure outcomes, and, probably, some proportion of undiagnosed cardiac pathology in SCI populations. Three studies reported prevalence in subgroups^48,^ ^50,^ ^52^ but not in the total sample. Conclusions and decisions based on pooled prevalence cannot be made.

#### Cardiovascular mortality

Mortality from CVDs was more consistent than prevalence across five studies that reported this outcome (Table 5).^1^–^3,^ ^49,^ ^52^ Patients with SCI died from diseases of the arteries (ICD codes 440–448) in 0.8^49^ to 1.5^2^ per 1,000 injured according to two large studies of more than 29,000 patients.^2,^ ^49^ CVD (ICD codes 390–458) caused death in 1 percent^49^ to 6.3 percent^1^ to 10 percent^52^ of those injured. Men with SCI had higher CVD mortality (5.3 percent) compared to women (1 percent), with no formal statistical test of the effect modification reported.^1^ Results were not controlled for potential differences in other CVD risk factors such as smoking status, diabetes, hypertension, and family history. Mortality increased with the age of the patients, being the highest after 75 years (10 percent).^52^ Less than 1 percent of SCI patients died from cerebrovascular diseases^1,^ ^2^ and stroke.^49^ Cerebrovascular deaths were more common in men (0.7 percent) than women (0.2 percent) with unknown statistical significance of the differences.^1^ Mortality from cerebrovascular diseases was 0.1 percent^2^ among patients with complete tetraplegia and 0.2 percent after cervical or thoracic injury with no functional motor preservation.^1^ Mortality from ischemic heart disease was <1 percent in two studies.^2,^ ^3^ One European study that obtained post mortem records found that 2.5 percent, including 2 percent men, died from ischemic heart disease.^1^ One long-term followup study in U.S. veterans reported a two-fold increase in mortality from 5 years (0.4 percent) to 20 years (0.9 percent) after injury, representing the association between age and mortality rather than SCI.^3^ Lung embolus caused death in 0.7 percent of patients with chronic SCI.^1^ Three studies reported that coronary heart disease was the primary cause of death in approximately 9 percent of patients with SCI (Figure 16). The proportion of deaths attributable to CVDs varied from 7.1 percent for ischemic heart disease^49^ to 24 percent for any CVD^1^ (Table 6). CVDs are among the leading causes of death in patients with chronic SCI;^1,^ ^49,^ ^52^ however, the contribution of age cannot be estimated by analyzing the crude proportion of aging SCI patients who died from heart diseases. One study of 402 veterans with chronic SCI followed for 55.6 months^36^ showed that diabetes (relative risk 2.62, 95 percent CI 1.19; 5.77) and heart diseases (relative risk 3.66, 95 percent CI 1.77; 7.78) were significant risk factors for death after adjustment for age.

Table 5 Mortality from CVD in adults with SCI

Author | Sample | Patient Characteristics | Mortality, % Among all SCI Patients
Arterial diseases
DeVivo, 1999^49^ | 28,239 | All SCI | 0.08
Time: 1973-1998
DeVivo, 1993^2^ | 9,135 | All SCI | 0.15
Time: 1973-1985 | | Ages 25–54 years | 0.04
| | Age >54 years | 0.10
| | Incomplete paraplegia | 0.03
| | Complete paraplegia | 0.03
| | Incomplete quadriplegia | 0.04
| | Complete quadriplegia | 0.04
| | Survival 1–5 years | 0.09
| | Survival >5 years | 0.01
Cardiovascular diseases
Garshick, 2005^36^ | 361 | All SCI | 2.2
Time: 1994-2000
Mean age: 50.6±15
DeVivo, 1999^49^ | 28,239 | All SCI | 1.03
Time: 1973-1998
Hartkopp, 1997^1^ | 888 | All SCI | 6.31
Time: 1954-1992 | | Thoracic-lumbar injury/Frankel A-C | 1.58
Median age at time of injury: 27.5 from 1953-1971 and 28.5 from 1972-1990 | | Frankel D | 3.04
| | Frankel E | 0.68
| | Cervical lesion | 0.00
| | Thoracic/lumbar lesion | 0.00
| | Men | 5.29
| | Women | 1.01
Whiteneck, 1992^52^ | 834 | All patients | 10.07
Time: 1943-1970 | | Paraplegia, ABC | 5.76
Age at time of injury 15–55, 42% 15–24 years, 27% 25–34 years, 18% 35–44 years, 13% 45–55 years; Median survival time 32 years | | Quadriplegia, ABC | 0.96
| | All D and E | 3.36
| | 15–24 | 0.08
| | 25–34 | 0.07
| | 35–44 | 0.24
| | 45–54 | 0.44
| | 55–64 | 1.33
| | 65–74 | 2.12
| | 75–84 | 10.20
Cerebrovascular diseases
Hartkopp, 1997^1^ | 888 | All patients | 0.90
Time: 1954-1992 | | Thoracic-lumbar injury/Frankel A-C | 0.23
Median age at the time of injury 27.5 in 1953-1971 and 28.5 in 1972-1990 | | Frankel D | 0.45
| | Frankel E | 0.00
| | Men | 0.68
| | Women | 0.23
DeVivo, 1993^2^ | 9,135 | All patients | 0.24
Time:1973-1985 | | Ages 25–54 years | 0.15
| | Age >54 years | 0.04
| | Incomplete paraplegia | 0.03
| | Complete paraplegia | 0.02
| | Incomplete quadriplegia | 0.09
| | Complete quadriplegia | 0.10
| | Survival 1–5 years | 0.12
| | Survival >5 years | 0.07
Ischemic heart disease
Hartkopp, 1997^1^ | 888 | All patients | 2.48
Time: 1954-1992 | | Thoracic-lumbar injury/Frankel A-C | 0.56
Median age at time of injury: 27.5 from 1953-1971 and 28.5 from 1972-1990 | | Frankel D | 1.13
| | Frankel E | 0.56
| | Men | 2.14
| | Women | 0.34
DeVivo, 1993^2^ | 9,135 | All patients | 0.67
Time: 1973-1985 | | Ages 25–54 years | 0.19
| | Age >54 years | 0.44
| | Incomplete paraplegia | 0.14
| | Complete paraplegia | 0.12
| | Incomplete quadriplegia | 0.23
| | Complete quadriplegia | 0.18
| | Survival 1–5 years | 0.27
| | Survival >5 years | 0.12
Rish, 1997^3^ | 230 | All patients | 0.02
Time: 1954-1992 | | Survival 5 years | 0.43
Mean age at injury 21.4 years, Median time after injury 25 years | | Survival 20 years | 0.87
| | Survival >20 years | 0.87
Lung embolus
Hartkopp, 1997^1^ | 888 | All patients | 0.68
Time: 1954-1992 | | Thoracic-lumbar injury/Frankel A-C | 0.11
Median age at time of injury 27.5 from 1953-1971 and 28.5 from 1972-1990 | | Frankel D | 0.34
| | Frankel E | 0.11
| | Men | 0.68
| | Women | 0.00
Non ischemic heart disease
DeVivo, 1993^2^ | 9,135 | All patients | 0.92
Time: 1973-1985 | | Ages 25–54 years | 0.31
| | Age >54 years | 0.47
| | Incomplete paraplegia | 0.04
| | Complete paraplegia | 0.11
| | Incomplete quadriplegia | 0.28
| | Complete quadriplegia | 0.48
| | Survival 1–5 years | 0.32
| | Survival >5 years | 0.18
Stroke
DeVivo, 1999^49^ | 28,239 | All patients | 0.19
Time: 1973-1998

Table 6 Percent of all deaths from CVD among adults with SCI

Author | Disease (ICD Codes) | % of all SCI Deaths
Hartkopp, 1997^1^ | CVD (390–458) | 24.0
| Ischemic heart disease (410–414) | 9.0
DeVivo, 1999^49^ | Heart | 18.8
DeVivo, 1993^2^ | Ischemic heart disease (410–414) | 7.1
Garshick, 2005^36^ | Circulatory system disorder (390–459) | 21.6
| Circulatory system disorder (390–459) as contributing cause of death | 18.9
Rish, 1997^3^ | Myocardial infarction | 8.8
Whiteneck, 1992^52^ | CVD | 23.2

Figure 16. Percent of all deaths due to coronary heart disease among adults with SCI

#### Cardiovascular prevalence and mortality in adults with chronic SCI compared to the general population according to age, race, and gender

Published evidence did not suggest that adults with chronic SCI experience CVDs more frequently than the general population. The Australian Risk Factor Prevalence Study of 327 patients with SCI and age and sex matched controls found that adults with SCI had a 50 percent reduction in arterial hypertension and no differences in odds of diabetes, myocardial infraction, angina pectoris, and cerebrovascular diseases (Table 7).^39^ Crude odds of arterial hypertension were lower by 84 percent^34^ in another study of 654 male veterans with SCI.^34^ The same study reported lower odds of congestive heart failure in injured compared to able-bodied veterans.^34^ The Stockholm Spinal Cord Injury Study showed that prevalence of circulatory diseases was lower by 75 percent in injured patients compared to healthy controls after adjustment for age, sex, socioeconomic status (odds ratio 0.25 p value = 0.014),^55^ with no differences in rates of cardiac diseases, and use of cardiac medications. One larger study of 18,372 veterans with SCI, 6,433 able-bodied veterans, and 221,650 in the general population, using 2003 Behavioral Risk Factor Surveillance System survey data,^37^ reported a three times higher rate of diabetes in injured veterans compared to the general population (20 percent versus 6.7 percent, odds ratio 3.32, 95 percent CI 1.34; 8.26),^37^ but similar odds compared to other veterans (21 percent, odds ratio 0.94, 95 percent CI 0.47; 1.87). SCI adults with diabetes had higher adjusted rates of coronary heart disease by 280 percent, myocardial infarction by 270 percent, arterial hypertension by 250 percent, and stroke by 230 percent compared to SCI patients without diabetes (Figure 17).^37^ Diabetes is associated with an increased risk of heart disease, independent of SCI. The authors did not compare relative risk of heart diseases in diabetics with and without injury to estimate the effect of injury.

Table 7 Odds ratios of diabetes or CVD in adults with SCI compared to able bodied

Conditions | Odds Ratio (95% CI)
| Lavela, 2006^37^VA Settings %; Mean Age 60 Years | Prakash, 2002^34^VA Settings Age 50±14 | Krum, 1992^39^Ages 25–64
Coronary heart disease | | 0.24 (0.13; 0.43)
Myocardial infarction | | | 1.00 (0.14; 7.24)†
Arterial hypertension | | 0.16 (0.12; 0.21) | 0.40 (0.17; 0.92) †
High cholesterol
Stroke
Diabetes | 3.3 (1.3; 8.3)* | 1.1 (0.88; 1.37) | 3.13 (0.62; 15.89) †
Congestive heart failure | | 0.24 (0.13; 0.43)
Angina | | | 0.67 (0.11; 4.1) †
Cerebrovascular diseases | | | 1.00 (0.06; 16.21) †

* Adjusted for age, race, marital status, duration of injury, employments status, and educational level

† Adjustment for age, matching by gender

Bold - significant association at 95% confidence level

Figure 17. Odds ratios* of cardiovascular outcomes in VA users with SCI and diabetes vs. SCI but no diabetes^37^

Odds ratios of cardiovascular outcomes were reported after adjustment for age. However, age may modify the association with injury and diabetes. For example, odds of diabetes were higher in injured veterans compared to the general population in all age groups but higher compared to able bodied veterans in those of 45–59, 55–59, and older than 70 years of age (Appendix E Table 4). Despite no difference in management of diabetes, adults with SCI and diabetes had three to five times higher rates of foot sores compared with diabetics in the general population and able-bodied veterans with diabetes. Risk of diabetic retinopathy was 19 percent higher compared to diabetics in the general population (Table 8).

Table 8 Diabetes management and diabetes complications in VA users with SCI, in VA users without SCI, and non-VA user general population without SCI^37^

Diabetes Management or Complications | Prevalence in VA SCI(%) | Prevalence in VA Non SCI(%) | Odds Ratio in VA SCI Compared to the VA Non SCI Population (95% CI) | Prevalence in Non VA General Population (%) | Odds Ratio in VA SCI Compared to Non VA General Population (95% CI)
Duration of diabetes (>25 years) | 13.55 | 10.94 | 1.27 (0.97; 1.66) | 9.75 | 1.44 (1.16; 1.79)
Insulin therapy | 26.03 | 28.51 | 0.88 (0.72; 1.08) | 25.9 | 1.01 (0.85; 1.19)
Oral agent | 62.97 | 69.54 | 0.75 (0.62; 0.90) | 66.35 | 0.86 (0.74; 1.01)
Insulin + oral agent | 11.25 | 12.82 | 0.86 (0.65; 1.13) | 11.17 | 1.00 (0.79; 1.27)
Foot sores with >4 weeks to heal | 41.37 | 17.85 | 3.25 (2.65; 3.98) | 13.12 | 4.68 (4.02; 5.46)
Retinopathy | 25.31 | 24.24 | 1.06 (0.86; 1.31) | 22.27 | 1.19 (1.00; 1.41)
Diabetes education | 63.04 | 60.16 | 1.13 (0.94; 1.36) | 49.84 | 1.72 (1.47; 2.00)

Bold - significant association at 95% confidence level

Evidence from one study suggested that neurological functional status may be associated with cardiovascular morbidity (Table 4). Patients with tetraplegia and no functional motor preservation had higher age adjusted odds ratio of cerebrovascular diseases, dysrhythmia, and valvular diseases and lower odds ratio of coronary heart disease compared to paraplegic patients (Figure 18). Adults with SCI and functional motor preservation had higher age adjusted odds of all CVDs, coronary atherosclerosis, dysrhythmia, and valvular disease compared to paraplegic and no functional motor preservation.^53^

Figure 18. Adjusted odds ratio of CVD in patients with SCI: Tetraplegia with no functional motor preservation compared to paraplegia and no functional motor preservation ^53^

Morbidity can be estimated using surrogate outcomes. ECG is the most important single diagnostic indicator of cardiac arrhythmias and myocardial infarction.^34^ One large study of 26,734 able-bodied male veterans and 654 patients with SCI found a decreased relative risk of ECG abnormalities in injured patients, only ST segment elevation in younger injured was observed more often in younger patients (Appendix E Table 5). Injured veterans with intact sympathetic innervation to the heart (injury level T6 and below) had lower risk of any ECG abnormalities compared to impaired sympathetic activity (injury level T5 and above) (Appendix E Table 6). Younger patients had lower risk of ECG abnormalities (Appendix E Table 7). Nearly all examined ECG abnormalities were associated with increased risk of death in able-bodied veterans, but only left bundle branch block (LBBB), left ventricular hypertrophy with strain, and atrial fibrillation accompanied the higher hazard ratio of death in patients with SCI (Table 9). Furthermore, these abnormalities were associated with a greater risk of dying in SCI compared to able-bodied adults. The rates of diagnosed hypertension (44 percent vs. 7 percent), congestive heart failure (7 percent versus 1.7 percent), and coronary heart diseases (7 percent versus 1.7 percent) were lower among SCI veterans compared to able-bodied (Figure 19).^34^ The contribution of undiagnosed heart disease on death in SCI patients is not known and requires future research.

Table 9 Hazard ratio of dying having ECG abnormality vs. normal ECG among patients with SCI and able-bodied veterans ^34^

ECG Abnormalities | Spinal Cord Injury Hazard Ratio 95% CI | Able-bodied Hazard Ratio 95% CI
Right bundle branch block | 1.23 (0.4; 4) | 2.21 (1.97; 2.47)
Left bundle branch block | 4.24 (1.5; 12) | 1.98 (1.62; 2.42)
Intraventricular conduction delay | 1.15 (0.3; 5) | 1.13 (0.99; 1.3)
LVH with strain | 3.28 (1.2; 9) | 1.31 (1.14; 1.52)
Left atrial abnormality | 0.59 (0.2; 1.9) | 1.55 (1.39; 1.74)
Anterior Q wave | 1.44 (0.5; 4.6) | 2 (1.76; 2.28)
Inferior Q wave | 0.78 (0.3; 1.8) | 1.32 (1.21; 1.43)
Atrial fibrillation | 3.54 (1.2; 11) | 2.02 (1.79; 2.27)
Premature ventricular contraction | 0.33 (0.05; 2.5) | 1.51 (1.36; 1.67)
Abnormal ST depression | 1 (0.5; 1.9) | 1.9 (1.77; 2.04)
Abnormal QT interval | 0.27 (0.1; 18) | 1.91 (1.77; 2.06)

Bold - significant association at 95% confidence level

Figure 19. Hazard ratio of dying based on ECG abnormality vs. normal ECG among VA users with SCI and able-bodied VA users^34^

In addition to reported relative risk, three studies^1,^ ^2,^ ^36^ estimated age standardized mortality ratios from CVDs in SCI patients compared to the general population (Tables 10 and 11). Injured patients died from all cardiovascular diseases more often than age matched able-bodied adults (standardized mortality ratio 2.1, 95 percent CI 1.83; 2.37.^1^ However, the ratio was significant only for lung embolus (standardized mortality ratio 11, 95 percent CI 4.19; 24.8) but not for other forms of CVD. SCI was associated with comparable increase in rates of cardiovascular death in men and women (Table 11). Cardiovascular mortality was lower in those injured after 1972 (standardized mortality ratio 2.4, 95 percent CI 1.95; 3.01) compared to those injured from 1953-1971 (standardized mortality ratio 7.1, 95 percent CI 2.31; 9.32) (Table 12).^1^ Standardized mortality ratios in patients with cervical (standardized mortality ratio 1.1, 95 percent CI 0.72; 1.53) or thoracic injuries (standardized mortality ratio 1, 95 percent CI 0.82; 1.84) did not differ from the general population in the European study of 888 injured adults followed up from 1953 to 1992.^1^

Table 10 Age standardized mortality ratios in adults with chronic SCI compared to the general population (no adjustment for other confounding factors)^2^

Risk Factors | Death (N) | Standardized Mortality Ratio(95% CI)
Ischemic heart disease (ICD codes 410–414)
Age 25–54 years | 17 | 1.4 (0.8; 2.0)
Age >54 years | 40 | 1.1 (0.8; 1.4)
Incomplete paraplegia | 13 | 1.4 (0.7; 2.1)
Complete paraplegia | 11 | 1 (0.4; 1.6)
Incomplete quadriplegia | 21 | 1 (0.6; 1.4)
Complete quadriplegia | 16 | 2.6 (1.3; 3.9)
Survival 1–5 years | 25 | 1.1 (0.7; 1.5)
Survival >5 years | 11 | 0.6 (0.2; 1.0)
Non ischemic heart disease (ICD codes 420–429)
Age 25–54 years | 28 | 6.5 (4.1; 10.8)
Age >54 years | 43 | 4.2 (3; 5.4)
Incomplete paraplegia | 4 | 1.4 (0.4; 2.4)
Complete paraplegia | 10 | 2.8 (1.1; 4.5)
Incomplete quadriplegia | 26 | 4 (2.5; 5.5)
Complete quadriplegia | 44 | 23.4 (16.5; 30.3)
Survival 1–5 years | 29 | 4.1 (2.6; 5.6)
Survival >5 years | 16 | 3 (1.5; 4.5)
Cerebrovascular diseases (ICD codes 430–438)
Age 25–54 years | 14 | 4.6 (2.2; 7.0)
Age >54 years | 4 | 0.4 (0; 0.8)
Incomplete paraplegia | 3 | 1.3 (0; 2.8)
Complete paraplegia | 2 | 0.8 (0; 1.9)
Incomplete quadriplegia | 8 | 1.4 (0.4; 2.4)
Complete quadriplegia | 9 | 5.4 (1.8; 9.0)
Survival 1–5 years | 11 | 2 (0.8; 3.2)
Survival >5years | 6 | 1.3 (0.2; 2.4)
Diseases of arteries (ICD codes 440–448)
Age 25–54 years | 4 | 8.2 (0.2; 16.2)
Age >54 years | 9 | 1.2 (0; 3.5)
Incomplete paraplegia | 3 | 5.4 (0; 11.5)
Complete paraplegia | 3 | 5 (0; 10.6)
Incomplete quadriplegia | 4 | 2.7 (0.1; 5.3)
Complete quadriplegia | 4 | 9.4 (0.2; 18.6)
Survival 1–5 years | 8 | 5.8 (1.8; 9.8)
Survival >5 years | 1 | 0.9 (0; 2.7)

Bold - significant association at 95% confidence level

Table 11 Age standardized mortality ratios for cardiovascular death by gender compared to able bodied^1^

Cause of Death | Standardized Mortality Ratio (95% CI)
| Men | Women | Both Genders
Period of injury 1953-1990 (end of followup: December 31, 1992)
CVD | 1.2 (0.85; 1.53) | 1 (0.52; 2.14) | 1.2 (0.87; 1.49)
Ischemic heart disease | 0.7 (0.41; 1.06) | 1 (0.14; 1.96) | 0.7 (0.42; 1.02)
Cerebrovascular disease | 1 (0.35; 2.07) | 1 (0.13; 3.98) | 1 (0.43; 1.94)
Lung embolus | 14 (5.25; 31.1) | | 11 (4.19; 24.8)
Total | 2.1 (1.79; 2.38) | 2 (1.53; 2.94) | 2.1 (1.83; 2.37)
Period of injury 1953-1971 (end of followup: December 31, 1973)
CVD | 3.2 (1.38; 6.29) | 4 (0.09; 19.5) | 3.2 (1.47; 6.12)
Ischemic heart disease | | | 1.1 (0.13; 3.91)
Cerebrovascular disease
Lung embolus | 131 (27.1; 384) | | 107 (22.1; 313)
Total | 6.5 (4.66; 8.74) | 12 (5.81; 22.3) | 7.1 (5.31; 9.32)
Period of injury 1972-1990 (end of followup: December 31, 1992)
CVD | 1.3 (0.71; 2.09) | 3 (0.86; 6.16) | 1.5 (0.89; 2.25)
Ischemic heart disease | 1.2 (0.58; 2.24) | | 1.2 (0.59; 2.13)
Cerebrovascular disease | | 4 (0.53; 15.9) | 1.4 (0.28; 3.96)
Total | 2.3 (1.79; 2.90) | 3 (1.91; 5.09) | 2.4 (1.95; 3.01)

Bold - significant association at 95% confidence level

Table 12 Age standardized mortality ratios from CVD in adults with SCI compared to the general population

Author Sample | Patient Characteristics | Mortality/1,000 SCI | Standardized Mortality Ratios (95% CI)
Artery diseases
DeVivo, 1993^2^ | Survival >5 years | 0.11 | 0.9 (0; 2.7)
N = 9,135 | Age >54 years | 0.99 | 1.2 (0; 3.5)
(standardization by age, sex, and race) | Incomplete quadriplegia | 0.44 | 2.7 (0.1; 5.3)
| All patients | 1.53 | 4.5 (2.1; 6.9)
| Complete paraplegia | 0.33 | 5 (0; 10.6)
| Incomplete paraplegia | 0.33 | 5.4 (0; 11.5)
| Survival 1–5 years | 0.88 | 5.8 (1.8; 9.8)
| Age 25–54 years | 0.44 | 8.2 (0.2; 16.2)
| Complete quadriplegia | 0.44 | 9.4 (0.2; 18.6)
Garshick, 2005^36^ | All patients | | 1.15 (0.13–4.15)
N = 361
Cerebrovascular diseases
DeVivo, 1993^2^ | Age >54 years | 0.44 | 0.4 (0; 0.8)
N = 9,135 | Complete paraplegia | 0.22 | 0.8 (0; 1.9)
(standardization by age, sex, and race) | Incomplete paraplegia | 0.33 | 1.3 (0; 2.8)
| Survival >5 years | 0.66 | 1.3 (0.2; 2.4)
| Incomplete quadriplegia | 0.88 | 1.4 (0.4; 2.4)
| All patients | 2.41 | 1.8 (1; 2.6)
| Survival 1–5 years | 1.20 | 2 (0.8; 3.2)
| Age 25–54 years | 1.53 | 4.6 (2.2; 7)
| Complete quadriplegia | 0.99 | 5.4 (1.8; 9)
Hartkopp, 1997^1^ | Men | 6.76 | 0.95 (0.35; 2.07)
N = 888 | All patients | 9.01 | 0.99 (0.43; 1.94)
| Women | 2.25 | 1.1 (0.13; 3.98)
Cardiovascular diseases
Hartkopp, 1997^1^ | Cervical lesion | | 1.07 (0.72; 1.53)
N = 888 | Women | 10.14 | 1.13 (0.52; 2.14)
| Men | 52.93 | 1.15 (0.85; 1.53)
| All patients | 63.06 | 1.15 (0.87; 1.49)
| Thoracic/lumbar lesion | | 1.26 (0.82; 1.84)
Ischemic heart disease
DeVivo, 1993^2^ | Survival >5 years | 1.20 | 0.6 (0.2; 1)
N = 9,135
(standardization by age, sex, and race)
Hartkopp, 1997^1^ | Women | 3.38 | 0.67 (0.14; 1.96)
N = 888 | Men | 21.40 | 0.68 (0.41; 1.06)
| All patients | 24.77 | 0.68 (0.42; 1.02)
DeVivo, 1993^2^ | Complete paraplegia | 1.20 | 1 (0.4; 1.6)
N = 9,135 | Incomplete quadriplegia | 2.30 | 1 (0.6; 1.4)
(standardization by age, sex, and race) | Age >54 years | 4.38 | 1.1 (0.8; 1.4)
| Survival 1–5 years | 2.74 | 1.1 (0.7; 1.5)
| All patients | 6.68 | 1.3 (1; 1.6)
| Age 25–54 years | 1.86 | 1.4 (0.8; 2)
| Incomplete paraplegia | 1.42 | 1.4 (0.7; 2.1)
| Complete quadriplegia | 1.75 | 2.6 (1.3; 3.9)
Lung embolus
Hartkopp, 1997^1^ | All patients | 6.76 | 11.4 (4.19; 24.8)
N = 888 | Men | 6.76 | 14.3 (5.25; 31.1)
Nonischemic heart disease
DeVivo, 1993^2^ | Incomplete paraplegia | 0.44 | 1.4 (0.4; 2.4)
N = 9,135 | Complete paraplegia | 1.09 | 2.8 (1.1; 4.5)
| Survival >5 years | 1.75 | 3 (1.5; 4.5)
| Incomplete quadriplegia | 2.85 | 4 (2.5; 5.5)
| Survival 1–5 years | 3.17 | 4.1 (2.6; 5.6)
| Age >54 years | 4.71 | 4.2 (3; 5.4)
| All SCI | 9.20 | 5.6 (4.4; 6.8)
| Age 25–54 years | 3.07 | 6.5 (4.1; 10.8)
| Complete quadriplegia | 4.82 | 23.4 (16.5; 30.3)
Diseases of the heart
Garshick, 2005^36^ | All patients | | 0.59 (0.19;1.38)
N = 361
Other diseases of the circulatory system
Garshick, 2005^36^ | All patients | | 1.49 (0.31;4.36)
N = 361

Bold - significant association at 95% confidence level

The role of functional status was reported in one study. Patients with complete tetraplegia died from ischemic heart disease (ICD codes 410–414) (standardized mortality ratio 2.6, 95 percent CI 1.3; 3.9), non ischemic heart diseases (standardized mortality ratio 23.4, 95 percent CI 16.5; 30.3), and cerebrovascular diseases (standardized mortality ratio 5.4, 95 percent CI 1.8; 9) more often than would be expected from the same age able-bodied adults.^2^

Mortality from nonischemic heart diseases (standardized mortality ratio 5.6, 95 percent CI 4.4; 6.8), artery diseases (standardized mortality ratio 4.5, 95 percent CI 2.1; 6.9), and lung emboli (standardized mortality ratio 11.4, 95 percent CI 4.2; 24.8) was higher in all injured adults compared to the general population.^2^ Mortality from lung emboli contributed the most to the overall differences within the total population. The role of carbohydrate and lipid disorders (the focus of this review) in nonischemic heart disease and biologic plausibility for this finding is not well known. Therefore, it is possible that these are spurious findings based on multiple comparisons.

Three studies reported that coronary heart disease constitutes approximately 9 percent among primary causes of death in SCI patients.^1^–^3^ The proportion of deaths attributable to all CVDs varied from 18.8 percent for diseases of the heart^49^ to 24 percent for circulatory system disorders.^1^ Cardiovascular diseases are among the leading causes of death in patients with chronic SCI.^1,^ ^49,^ ^52^ However, the contribution of age cannot be estimated analyzing crude proportion of aging SCI patients who died from heart diseases. One study of 402 veterans with chronic SCI followed by 55.6 months^36^ showed that diabetes (relative risk 2.62, 95 percent CI 1.19; 5.77) and heart diseases (relative risk 3.66, 95 percent CI 1.77; 7.78) were significant risk factors for death after adjustment for age.

The role of lipid disorders to increase the risk of cardiovascular morbidity and mortality has not been evaluated in the published articles. The Australian Risk Factor Prevalence Study examined the overall cardiovascular risk in 102 injured patients and age matched control with scores from the MRFIT study (age, diastolic blood pressure, total cholesterol level, cigarettes per day, and sex).^39^ The injured patients had overall percentile position of risk <50 percent independent of age and years after injury. The authors concluded that increased blood pressure, elevated blood cholesterol, or smoking could not explain cardiovascular prevalence in SCI patients.^39^ Physical activity, BMI, cigarette use, and alcohol consumption were not associated with increased risk of cardiovascular diseases in the study of 97 injured adults.^54^ However, the size of this study was too small to rule out clinically meaningful associations. One study showed that diabetes in SCI patients was associated with an increased risk of coronary heart disease, myocardial infarction, arterial hypertension, high cholesterol, and stroke, the well known association in able-bodied adults.^37^

#### Interpretation of findings

Published evidence suggested that for people with SCI, diabetes mellitus contributed to an increased risk of CVDs.^37^ The role of metabolic syndrome and lipid disorders had not yet been investigated. Increased rates of diabetes in SCI compared to able-bodied adults were reported in three articles^30,^ ^32,^ ^37^ with no differences in the other three.^34,^ ^39,^ ^55^ The degree of neurological impairment may be associated with cardiovascular mortality in SCI patients with no documented evidence of independent contribution of glucose and lipid disorders. Cardiovascular morbidity varied substantially among studies, being highest in injured veterans. Many important confounders might explain such differences beyond the veteran status, since many veterans do not seek care from the VA.^74^ The studied veterans are more likely to be poor, without private insurance, have minority status, and/or have a service connected injury.^74^ Indirect comparisons of cardiovascular morbidity in injured patients with known incidence of CVD in the general population does not permit and accurately estimate the contribution of metabolic disorders in patients with SCI.

##### Summary

Cardiovascular diseases are among the leading causes of death in patients with chronic SCI. However, when compared to able-bodied adults, cardiovascular prevalence in SCI patients did not show significant differences.

a Cardiovascular mortality in injured patients was compared to standardized by age mortality in the general population in three studies. Age adjusted mortality from nonischemic heart diseases (standardized mortality ratio 5.6, 95 percent CI 4.4; 6.8), artery diseases (standardized mortality ratio 4.5, 95 percent CI 2.1; 6.9), and lung emboli (standardized mortality ratio 11.4, 95 percent CI 4.2; 24.8) was higher in all injured adults compared to the general population. Cardiovascular mortality was lower in those injured after 1972 (standardized mortality ratio 2.4, 95 percent CI 1.95; 3.01) compared to those injured from 1953-1971 (standardized mortality ratio 7.1, 95 percent CI 2.31; 9.32).
  Limited inconsistent evidence suggested higher risk of morbidity and mortality in adults who were older at time of injury. The role of functional status was examined in two studies reporting that patients with tetraplegia had higher odds of having and dying from cerebrovascular diseases. Inconsistent evidence suggested that patients with complete tetraplegia died from ischemic heart disease (standardized mortality ratio 2.6, 95 percent CI 1.3; 3.9) and nonischemic heart diseases (standardized mortality ratio 23.4, 95 percent CI 16.5; 30.3) more often than would be expected from the same age able-bodied adults. However, these findings may be based on chance due to the multiple comparisons and lack of significant associations with other cardiovascular outcomes.
b Diabetes contributed to higher risk of CVD in veterans with SCI compared to nondiabetic SCI veterans in one large study. No studies compared risk of CVD among diabetics with SCI to able-bodied diabetics. The role of lipid disorders to increase the risk of cardiovascular morbidity and mortality has not been evaluated in the published articles. One study concluded that increased blood pressure, elevated blood cholesterol, or smoking could not explain increased cardiovascular prevalence in SCI patients.

### Question 3

#### Exercise in adults with SCI

Of the 19 peer reviewed original articles, there were none reporting results of RCTs. The majority consisted of small, uncontrolled intervention trials (case series) or cross-sectional surveys using measures of self-reported physical activity. Variation in study design, intervention, and reported outcomes precluded quantitative pooling of results. A summary of findings from individual studies according to intervention type and outcomes was conducted. To facilitate review, these studies were separated by outcomes of interest: Carbohydrate-related outcomes (n=10) (Table 13) and lipid-related outcomes (n=13) (Table 14). These were then further organized by type of reported exercise, as follows:

A Active Exercise (AE): n=six studies of 57 individuals (40 males, five females, 12 unreported; 36 paraplegic, three tetraplegic, nine unclassified and nine other) (8–24 weeks exercise duration).^57^–^63^
B Functional Electrical Stimulation Exercise (FES): n=five studies of 32 individuals (27 males, five females; eight paraplegic, 14 tetraplegic and ten unclassified) (8–52 weeks exercise duration)^64^–^68^
C Passive Exercise (PE): n=0 studies
D Self-Reported Physical Activity: n=six studies of 215 individuals (205 males, 14 females; 125 paraplegic, 93 tetraplegic, one unclassified) (no report of duration)^13,^ ^14,^ ^54,^ ^69^–^71^
E Other: n=one study (nine males, seven females) (no report of duration)^72^

Table 13 Description of exercise intervention studies with carbohydrate related outcomes in people with SC

Reference | Study Design; Sample Size | Intervention Type | Frequency; Intensity; Duration | Subject Characteristics | Outcomes of Interest | Findings
A. Active exercise
de Groot, 2003^58^ | Case series | Arm crank exercise | 3 sessions/week; | 4 males, 2 females; Age range 19–54 years; | Insulin sensitivity (post-test/pre-test) | Nonsignificant decline in HI group (67%±9%) and nonsignificant improvement in LI group (156%±55%) from baseline
| n=6 | | 60 minutes/session; High-intensity (HI; 70–80% heart rate reserve (HRR)) vs. low-intensity (LI; 40–50% HRR) | Mean duration since injury 116±77 days;
| Random assignment to high vs. low intensity | | 8 weeks of training | 6 paraplegic (C5-L1)
Midha, 1999^60^ | Case series | Wheelchair aerobic fitness trainer (WAFT) training program | 2–3 sessions/week; | 11 males, 1 female; | Fasting serum glucose (mg/dL) | No change from pre-training to post-training (86±35 to 85±32)
| n=12 (Includes 2 nonSCI subjects) | | 20–30 minutes, until target heart rate of 90% age-predicted maximum reached; mean intensity 177 watts | Age range 22–58;
| | | 10 weeks of training | Duration since injury range 4–29 years;
| | | | 3 quadriplegic;
| | | | 7 paraplegic;
| | | | 1 stroke;
| | | | 1 amputee
Phillips, 2004^62^ | Case series | Body-weight supported treadmill training program | 68 sessions (2.8±0.2 sessions/week); | 8 males, 1 female; | A Glucose tolerance (area under glucose × time curve); B Blood insulin concentration (area under insulin × time curve) | A 15%±4% (range 6–26%) reduction from baseline (p <.05); B 33%±8% (range 17–47%) reduction from baseline (p <.01)
| n=9 | | Velocity and % weight supported varied for each participant; | Mean age 31±3 years;
| | | 6.0±0.3 months of training | Mean duration since injury 8.1 years;
| | | | 9 incomplete (C4-T12)
B. Functional electrical stimulation exercise
Chilibeck, 1999^64^ | Case series | Electrically stimulated leg cycling program | 3 sessions/week; | 4 males, 1 female; | A Glucose tolerance (area under glucose × time curve); B Fasting serum insulin (area under insulin × time curve); C Insulin sensitivity index | A Nonsignificant decreases from pre-training to post-training; B Nonsignificant decreases from pre-training to post-training; C Increase from pre-training (~0.9) to post-training (~1.3) (p <.05)
| n=5 | | 30 minutes/session; | Age range 31–50 years;
| | | Power 6.0 watts, increased as possible each session; | Duration since injury range 3–25 years;
| | | 50 revolutions/minute; | 5 complete (C5-T8)
| | | 8 weeks of training
Hjeltnes, 1998^65^ | Case series | Electrically stimulated leg cycling program | 7 sessions/week; | 5 males, 0 females; | A Insulin-mediated glucose disposal (uM/kg/minute); B Mean steady-state insulin (uU/mL); C Mean steady-state glucose (mM) | A 33%±13% increased whole body insulin-stimulated glucose uptake from baseline (p <.05); B No change from pre-training to post-training (97±1 to 94 ±1); C No change from pre-training to post-training (5.8±0.4 to 5.9±0.4)
| n=5 | | 30 minutes/session or until fatigued; | Mean age 35±3 years;
| | | Power 6.0 watts, increased by 6.1 watts each session; | Mean duration since injury 10.2±3.4 years;
| | | 50 revolutions/minute; | 5 tetraplegic;
| | | 8 weeks of training | 5 complete (C5–C7)
Jeon, 2002^66^ | Case series | Electrically stimulated leg cycling program | 3 sessions/week; | 5 males, 2 females; | A 2-hour postload glucose (mg/dL);; B 2-hour postload insulin (uU/mL) | A Reduction from pre-training to post-training (139.9±16 to 122.4±10; p = .014);; B Nonsignificant reduction from pre-training to post-training (118.4±42.6 to 87.5±10)
| n=7 | | 30 minutes/session; | Age range 30–53 years;
| | | 50–60% VO2 maximum; | Duration since injury range 3–40 years;
| | | 8 weeks of training | 3 tetraplegic
| | | | 4 paraplegic
| | | | 7 complete (C5-T10)
Mahoney, 2005^67^ | Case series | Resistance exercise training program | 2 sessions/week; | 5 males, 0 females; | A Plasma glucose levels (mg/dL); B Insulin concentration | A Nonsignificant trend for reduction from pre-training to post-training (p = .074); B No change from pre-training to post-training
| n=5 | | 4 sets of 10 unilateral, dynamic knee extensions; | Mean age 35.6±4.9 years;
| | | 12 weeks of training | Mean duration since injury 13.4±6.5 years;
| | | | 5 complete (C5-T9)
Mohr, 2001^68^ | Case series | Exercise program with functional electrical stimulation cycling ergometer | 3 sessions/week; | 8 males, 2 females; | A 2-hour postload insulin (uU/mL); B 2-hour postload glucose (mM/L); C Insulin-stimulated glucose uptake rates (mg/min/kg) | A No change from pre-training to post-training (93±7 to 88±8); B No change from pre-training to post-training; C Increased from pre-training to post-training (4.9±0.5 to 6.2±0.6; p <0.05)
| n=10 | | 30 minutes/session; | Mean age 35±2 years;
| | | 50 revolutions/minute; | Mean duration since injury 12±2;
| | | 1 year of training | 6 tetraplegic (C6);
| | | | 4 paraplegic (T4)
C. Passive exercise
No eligible studies
D. Self-reported physical activity
Jones, 2004^14^ | Cross-sectional case-control survey | NA | NA | 20 males, 0 females; | A Fasting plasma glucose (mM/L); B Log 2-hour postload glucose (mM/L); C Log fasting plasma insulin (uU/mL); D Log 2-hour postload insulin (uU/mL) | A Nonsignificant inverse association with physical activity (r = -0.40); B Inverse association with physical activity (r = -0.59; p <.01); C No association with physical activity (r = -0.07); D Inverse association with physical activity (r = -0.79; p <.01)
| n=20 | Assessed physical activity levels (minutes/week) and metabolic variables | | Age range 16–52 years;
| | | | Mean duration since injury 10.3±1.8 years;
| | | | 11 tetraplegic (C4–C7);
| | | | 9 paraplegic (T5-L5)
Manns, 2005^13^ | Cross-sectional survey | NA | NA | 22 males, 0 females; | A Fasting plasma glucose (mM/L); B 2-hour postload glucose (mM/L); C Fasting plasma insulin (uM/ml); D 2-hour postlload insulin (uM/ml) | A Inverse association with physical activity (r = -0.525; p <.05); B Nonsignificant inverse association with physical activity ( r= -0.34); C Nonsignificant inverse association with physical activity (r = -0.40); D No association with physical activity (r = -0.16)
| n=22 | Assessed physical activity levels and metabolic variables | | Mean age 39±-9 years;
| | | | Mean duration since injury 17±9 years;
| | | | 22 paraplegic (T2-L2);
| | | | 22 complete
E. Other
No eligible studies

Table 14 Description of exercise intervention studies with lipid or cardiovascular related outcomes in people with SCI

Reference | Study Design; Sample Size | Intervention Type | Frequency; Intensity; Duration | Subject Characteristics | Outcomes of Interest | Findings
A. Active exercise
Durán, 2001^57^ | Case series | Training program including mobility, strength, coordination, aerobic resistance, and relaxation activities | 3 sessions/week; | 12 males, 1 female; | A HDL (mg/dL); B LDL (mg/dL); C TC/HDL | A No change from pre-training (38±11.6) to post-training (p <008); B No change from pre-training (94±39.8) to post-training (p <0.25); C No change from pre-training (4.75+/-2.15) to post-training (p <0.076)
| n=13 | | 120 minutes/session; | Mean age 26.3±8.3 years;
| | | Target HR 40%–80% of maximal HR; | Duration since injury range 2–120 months;
| | | 16 weeks of training | 13 paraplegic
| | | | 4 T6 or higher;
| | | | 9 T6 or lower
de Groot, 2003^58^ | Case series | Arm crank exercise program | 3 sessions/week; | 4 males, 2 females; | A TC (post-test/pre-test); B HDL (post-test/ pre-test); C LDL (post-test/pre-test); D TC/HDL-C (post-test/pre-test); F TG (post-test/pre-test) | A No significant differences for HI or LI groups (-11% and -6%); B No significant differences for HI or LI groups (+13% and -5%); C No significant differences for HI or LI groups (-14% and -5%); D Reduction in HI group (-23%) but not LI group (0%); F Reduction in HI group (31%) but not LI group (-5%)
| n=6 | | 60 minutes/session; | Age range 19–54 years;
| Random assignment to high vs. low intensity | | High intensity (HI; 70–80% heart rate reserve) vs. low intensity (LI; 40–50% HRR); | Mean duration since injury 116±77 days;
| | | 8 weeks of training | 6 paraplegic (C5-L1)
El-Sayed, 2005^59^ | Controlled case series | Arm crank exercise program | 3 sessions/week; | 5 paraplegic (SCI); | A TC (mM/L); B HDL-C (mM/L); C TG (mM/L) | A No change from pre-training to post-training in AB or SCI; B Increase (p <0.05) from pre-training to post-training in SCI; C No change from pre-training to post-training in AB or SCI
| n=12 | | 30 minutes/session; | 7 able-bodied (AB);
| | | 60–65% VO2 peak; | Mean age 32±1.6 years for AB;
| | | 12 weeks of training | Mean age 31±2.9 years for SCI
Midha, 1999^60^ | Case series | WAFT training program | 2–3 sessions/week; | 11 males, 1 female; | A TC (mg/dL); B TG (mg/dL); C HDL-C (mg/dL); D TC/HDL-C | A Reduction from pre-training to post-training (185±42 to 170±32, p = 0.04); B No change from pre-training to post-training (117±52 to 110±60); C No change from pre-training to post-training (48±10 to 48±10); D No change from pre-training to post-training (4±1 to 3.8±1)
| n=12 (includes 2 non-SCI subjects) | | 20–30 minutes, until target heart rate of 90% age-predicted maximum reached; | Age range 22–58;
| | | Mean intensity 177 watts; | Duration since injury range 4–29 years;
| | | 10 weeks of training | 3 tetraplegic;
| | | | 7 paraplegic;
| | | | 1 stroke;
| | | | 1 amputee
Nash, 2001^61^ | Case series | Arm crank exercise program, with focus on resistance and endurance | 3 sessions/week; | 5 males, 0 females; | A TC (mg/dL); B HDL (mg/dL); C LDL (mg/dL); D TC/HDL-C; E TG (mg/dL) | A Nonsignificant decrease pre-training to post-training (183±26 to 167±33); B Nonsignificant increase pre-training to post-training (41±5 to 45±12); C Decrease pre-training to post-training (118±22 to 88±30, p = 0.05); D Decrease pre-training to post-training (5.0±1.1 to 3.9±0.7, p = 0.05); E Nonsignificant decrease pre-training to post-training (202±120 to 190±91)
| n=5 | | 45 minutes/session; | Age range 34–43 years;
| | | Power output 400 kpm + 100 kpm every 3 minutes until peak VO2 maximum; | Mean duration since injury 4.8±1.4 years;
| | | 3 months of training | 6 paraplegic;
| | | | 5 complete (T6-L1)
Stewart, 2004^63^ | Case series | Body-weight supported treadmill training program | 68 sessions (2.8±0.2 sessions/week); | 8 males, 1 female; | A TC (mM); B HDL-C (mM); C LDL-C (mM); D TC/HDL-C (mM); E TG (mM) | A Decrease from pre-training to post-training (4.9±0.2 to 4.4±0.1, p = 0.021); B Nonsignificant increase pre-training to post-training (1.3±0.2 to 1.4±0.3, p = .19); C Decrease from pre-training to post-training (3.3±0.2 to 2.8±0.3, p = 0.046); D Decrease from pre-training to post-training (3.8±0.3 to 3.1±0.3, p = .041); E Nonsignificant decrease pre-training to post-training (1.5±0.2 to 1.3±0.2, p = .17)
| n=9 | | Velocity and % weight support varied for each participant; | Mean age 31±3 years;
| | | 6.0±0.3 months of training | Mean duration since injury 8.1 years;
| | | | 9 incomplete (C4-T12)
B. Functional electrical stimulation exercise
No eligible studies
C. Passive exercise
No eligible studies
D. Self-reported physical activity
Dallmeijer, 1999^70^ | Case-series survey | NA | NA | 15 males, 4 females; | A Difference TC (mM/L); B Difference LDL-C (mM/L); C Difference TC/HDL-C (mML); D TG (mM/L) | A Inverse association with sport activity (r = -0.35; p = 0.008); B Inverse association with sport activity (r = -0.28; p = 0.003); C Inverse association with sport activity (r = -0.49; p = 0.035); D No change in values from t1 to t2
| n=19 | Assessed risk profiles and sport activity (hours/week) at t1 (during rehab) and t2 (1 year post-discharge) | | Mean age 40.7±14.7 years;
| | | | Mean duration since injury 760±169 days;
| | | | 9 tetraplegic;
| | | | 10 paraplegic
Dallmeijer, 1997^69^ | Cross-sectional survey | NA | NA | 24 males, 0 females | A TC (mM/L); B HDL (mM/L); C LDL-C (mM/L); D TC/HDL-C; E TG | A No difference between groups; B Higher for physically active (1.1±0.21) than sedentary (0.95±0.20) (p <0.05); C No difference between groups; D Lower for physically active (1.34±0.67) than sedentary (1.96±1.01) (p <0.05); E Nonsignificantly lower for physically active (1.34±0.67) than sedentary (1.96±1.01)
| n=24 | Compared lipid levels between physically active (1.5–6.0 hours/week) and sedentary SCI patients | | 11 physically active
| | | | 13 sedentary
| | | | 24 tetraplegic
| | | | 4 incomplete
| | | | 20 complete
Davies, 2002^54^ | Cross-sectional survey | NA | NA | 87 males, 10 females; | Cardiovascular morbidity | No association with physical activity
| n=97 | Assessed physical activity as determinant of cardiovascular morbidity (both measurements made with valid and reliable scale) | | Mean age 47.5±4.5 years;
| | | | Mean duration since injury 15.9±10.1 years;
| | | | 41 tetraplegic
| | | | 55 paraplegic
| | | | 1 undetermined
| | | | 32 complete
| | | | 62 incomplete
| | | | 3 undetermined
Janssen, 1997^71^ | Cross-sectional survey | NA | NA | 37 males, 0 females; | A TC (mM/L); B HDL (mM/L); C LDL-C (mM/L); E TC/HDL-C; F TG | A Inverse association with physical activity (r = -0.33; p <0.05); B No association with physical activity (r = -0.14); C Inverse association with physical activity (r = -0.40; p <0.01); E No association with physical activity (r = -0.17); F No association with physical activity (r = 0.06)
| n=37 | Assessed sport activity (hours/week) as determinant of lipid profiles | | Age range 19–71 years;
| | | | Duration since injury range 4–33 years;
| | | | 8 tetraplegic
| | | | 29 paraplegic
| | | | 23 complete
Jones, 2004^14^ | Cross-sectional case-control survey | NA | NA | 20 males, 0 females; | A TC/HDL (mM/L); B Log HDL (mM/L) | A Inverse association with physical activity (r = -0.49; p <0.05); B Direct association with physical activity (r = 0.46; p <0.05)
| n=20 | Assessed physical activity levels (minutes/week) and metabolic variables | | Age range 16–52 years;
| | | | Mean duration since injury 10.3±1.8 years;
| | | | 11 tetraplegic (C4–C7)
| | | | 9 paraplegic (T5-L5)
Manns, 2005^13^ | Cross-sectional survey | NA | NA | 22 males, 0 females; | A HDL-C (mM/L); B TG (mM/L) | A Direct association with physical activity (r = 0.625; p <0.05); B No association with physical activity (r = -0.256)
| n=22 | Assessed physical activity levels and metabolic variables | | Age range 39±9 years;
| | | | Mean duration since injury 17±9 years;
| | | | 22 paraplegic (T2-L2);
| | | | 22 complete
E. Other
Chen, 2006^72^ | Case series | NA | Followup testing at 12 weeks and 24 weeks | 9 males, 7 females; | A TC (mg/dL); B HDL-C (mg/dL); C LDL-C (mg/dL) | A Nonsignificant decrease pre-program to post-program (-5.8±20.9, p = 0.28); B Decrease from pre-program to post-program (-3.2±5.4, p = .03); C Nonsignificant decrease pre-program to post-program
| n=16 | Participation in weight management program where exercise behavior was taught | | Age range 21–66 years; | | (-1.8±22.1, p = .76)
| | | | Mean duration since injury 17.5 years
| | | | 15 SCI
| | | | 1 spinal cord illness

##### Description of exercise intervention studies with carbohydrate related outcomes (Table 13) (n=10 studies of 101 individuals).^13,^ ^14,^ ^58,^ ^60,^ ^62,^ ^64^–^68^

The overall quality, quantity, and consistency of evidence for exercise as an intervention for carbohydrate disorders is poor. Study characteristics ranged from a case series using pre-post assessment of outcomes for six individuals randomly assigned to eight weeks of high- versus low-intensity arm crank exercise^58^ to a cross-sectional survey of 22 individuals who provided self-assessed physical activity levels and metabolic variables.^13^ The intervention type, frequency, intensity, and duration varied considerably across studies. Most involved several sessions of supervised exercise per week with a study duration ranging from eight weeks to one year. SCI level and severity, and duration since injury, varied across studies. More than 90 percent of subjects were men. One study was a survey of self-reported exercise or physical activity and assessed the impact of the respondent's activity on major cardiovascular endpoints.^54^ Three studies examined the effects of active exercise (AE),^58,^ ^60,^ ^62^ while five examined the effects of FES exercise,^64^–^68^ on carbohydrate related measures. Two survey studies assessed the association between self-reported physical activity and these measures.^13,^ ^14^ The most commonly assessed measures were fasting plasma glucose and oral glucose tolerance tests, measuring post-oral load levels of glucose and insulin. None assessed glycosylated hemoglobin.

##### Impact of exercise programs on carbohydrate related measures

There is mixed, low-quality evidence that a program of exercise improves carbohydrate-related measures. Of the five studies that measured fasting plasma glucose only one showed a statistically significant difference. Two (one AE; one FES) found no differences before and after intervention,^60,^ ^65^ while one FES study found a nonstatistically significant trend for reduction.^67^ Two surveys identified inverse correlations (r = -.53 and -.40 respectively) between self-reported physical activity and plasma glucose; one was statistically significant^13^ while the other was not.^14^ Measures of two-hour post-load glucose were mixed. One FES study found a significant (p = .014), 13 percent post-training reduction in glucose levels, averaged across participants,^66^ while another FES study showed no change.^68^ Both survey studies of self-reported physical activity identified inverse correlations (r = -.59 and -.34 respectively) with two-hour post-load glucose; the prior was statistically significant (p <0.01)^14^ while the latter was not.^13^ Impaired glucose tolerance and clearing were also reported. One AE study showed a statistically significant post-training 15 percent average reduction in area under the curve after glucose load,^62^ and one FES study found a significant 33 percent average increase in glucose disposal.^65^

Measures of insulin levels were no more uniform than for glucose. Some studies assessed fasting insulin levels, while others assessed insulin levels after a standard glucose load or insulin area under the curve. One possible consistency in these studies is the lack of change in fasting plasma insulin levels after training. Two FES studies found no difference in fasting plasma insulin,^65,^ ^67^ while one identified decreased levels that were not significant.^64^ One survey study showed no correlation between self-reported physical activity and insulin;^14^ the other survey study did identify an inverse correlation (r = -.40), but it was not statistically significant (p >0.05).^13^ Plasma insulin concentrations after oral glucose load were also inconsistent. One FES study identified a nonsignificant 26 percent average reduction in two-hour post-load levels,^66^ while another FES study found no change.^68^ Similarly, one survey study identified a statistically significant inverse correlation (r = -.79. p <0.01) between self-reported physical activity and post-load insulin,^14^ while the other found no correlation.^13^ One AE study identified a significant 33 percent average reduction in area under the curve for plasma insulin concentrations after glucose load.^62^ To further complicate any possible conclusions, the AE study comparing two programs of exercise (low intensity vs. high intensity)^58^ found insulin sensitivity to be decreased by an average of 33 percent for those assigned the low intensity intervention, but increased an average of 56 percent for those in the high intensity intervention.

##### Description of exercise intervention studies with lipid or cardiovascular related outcomes (Table 14) (n=13 studies of 292 individuals).^13,^ ^14,^ ^54,^ ^57^–^61,^ ^63,^ ^69^–^72^

The quality, quantity, and consistency of evidence for studies reporting lipid related measures is also poor. Study designs were primarily reports of case series and cross-sectional surveys, with intervention type, frequency, intensity, and duration varied across studies. Nearly 90 percent of subjects were men, thus limiting extrapolation of findings in women. Six studies examined the effects of AE on lipid related measures.^57^–^61,^ ^63^ No eligible studies examined FES exercise. There were six survey studies that assessed the association between self-reported physical activity and lipid measures.^13,^ ^14,^ ^54,^ ^69^–^71^ One of these examined the association between physical activity and cardiovascular morbidity.^54^ One study, categorized as “other,” examined the effects of a weight management training program, including curriculum on exercise, on lipid outcomes.^72^ The most common lipid related measures were TC, HDL-C, LDL-C, the ratio of TC to HDL-C (TC/HDL-C), and TG.

##### Impact of exercise programs on lipid or cardiovascular related measures

Evidence may point to improved levels of TC after a training intervention, or with self-reported physical activity. Among the studies examining effects of AE interventions, two identified statistically significant reductions in TC levels (on average, 8 percent and 10 percent less than pre-training);^60,^ ^63^ these involved training programs with a body-weight supported treadmill^63^ or a wheelchair aerobic fitness trainer.^60^ One study found a nonsignificant 9 percent average decrease,^61^ while two showed no changes;^58,^ ^59^ all three of these studies involved arm crank exercise. Three survey studies examined self-reported exercise and TC levels.^69^–^71^ While one found no difference in TC levels between those who were physically active and those who were sedentary,^69^ two others identified significant inverse correlations (r = -.35 and -.33, p = 0.008 and p <0.05, respectively). The study examining the weight management training program also identified a nonsignificant decrease in TC.^72^

Six AE studies reported outcomes for HDL-C.^57^–^61,^ ^63^ While three reported no changes,^57,^ ^58,^ ^60^ one reported a statistically significant increase^59^ and two reported very small, nonsignificant increases (10 percent and 8 percent).^61,^ ^63^ Four survey studies reported on HDL-C, with one identifying a significantly significant 14 percent decrease (p <0.05) for individuals who were physically active compared to those who were sedentary.^69^ Two others identified significant positive correlations (r = .46 and .63, p <0.05),^13,^ ^14^ while another reported no correlation.^71^ Oddly, the weight management study reported a significant decrease in HDL-C.^72^ Measures for TC/HDL-C were similarly inconclusive. Of five AE studies, two reported no changes,^57,^ ^60^ while three reported statistically significant reductions in values ranging from 18 percent to 23 percent.^58,^ ^61,^ ^63^ Two survey studies identified significant inverse correlations between physical activity and TC/HDL-C (r = -.49, p <0.05 for both),^14,^ ^70^ one identified a significant reduction (p <0.05) among those who were physically active compared to sedentary,^69^ and one showed no correlation.^71^

In two of four AE studies reporting LDL-C measures, levels were significantly decreased by 15 percent and 25 percent (p = .05 for both);^61,^ ^63^ no changes were observed in the others.^57,^ ^58^ However, two of three survey studies identified significant inverse correlations between self-reported physical activity and LDL-C levels (r = -.28 and -.40, p = 0.003 and p <0.01 respectively).^70,^ ^71^ The third survey study found no difference between groups.^69^ The weight management program was associated with a nonsignificant decrease.^72^

While one study identified a statistically significant 31 percent average decrease in TG among those assigned a high intensity AE training protocol,^58^ two others showed decreases that were nonsignificant,^61,^ ^63^ and still two others found no change.^59,^ ^60^ Among the four self-report surveys, one identified a nonsignificant 32 percent decrease among those who were physically active compared to sedentary.^69^ Three others identified no correlation between physical activity and TG levels.^13,^ ^70,^ ^71^

The study by Davies and McColl^54^ identified no association between physical activity levels and overall cardiovascular morbidity.

##### Summary

Evidence on effects of exercise on lipid and carbohydrate metabolism disorders is inconclusive. Studies to date have been short in duration, involved few subjects, and relied on study designs highly susceptible to error. Future collaborative research is needed to study both efficacy and effectiveness of such interventions in the population of individuals with SCI.

#### Dietary and pharmacologic intervention studies with carbohydrate or lipid related outcomes in adults with SCI

##### Carbohydrate outcomes

There were no prospective studies that evaluated dietary and/or lifestyle interventions on carbohydrate related outcomes.

##### Lipid related outcomes (Table 15.)

Only two prospective studies that evaluated dietary and/or lifestyle interventions to reduce lipid levels were identified and met inclusion criteria.^20,^ ^72^ No studies assessing pharmacologic interventions were identified. The two dietary/lifestyle case series studies included 238 subjects, overwhelmingly male (87 percent). Quality of the two studies was poor.

Table 15 Diet and pharmacologic therapy studies for prevention and/or treatment of carbohydrate and lipid metabolism disorders in people with spinal cord injury and disease

Reference | Intervention Type | Subject Characteristics; Duration | Outcomes of Interest | Findings
Study Design
A. Diet therapy
Szlachcic, 2001^20^ | Group 1 (subjects had total cholesterol >200mg/dl): Dietary intervention referral (Seen ≥2 times/week, followed recommendations of American Heart Association and American Dietetic Association Guidelines) (n=86) | 222 subjects with SCI ≥2 years. | A TC; B LDL; C TG; D HDL | [underlined: Comparison of baseline to followup values]
Clinical controlled trial | Group 2 (subjects had total cholesterol <200mg/dl): Not referred for dietary intervention (n=136) | Male 89% (n=198), females 11% (n=24). | | A. TC
| | Mean age 38.5±11 years | | Group 1: 234±31 to 224±34, p <0.001
| | White: 22% (n=49) | | Group 2: 162±23 to 166±30, p = 0.06
| | African American: 21% (n=47) | | B. LDL
| | Hispanic: 54% (n=120) | | Group 1: 159±28 to 151±28, p = 0.004
| | Asian: 2% (n=4) | | Group 2: 101±21 to 104±27, p not significant
| | Mean duration since injury | | C. TG
| | Group 1 subjects significantly older (42.8 vs. 35.7, p <0.0001) and had longer post-injury duration (15.6 vs. 11.1, p <0.0001). | | Group 1: 183±161 to 162±103, p not significant
| | Paraplegia, complete: 38% | | Group 1: 99±59 to 104±71, p not significant
| | Paraplegia, incomplete: 12% | | D. HDL
| | Tetraplegia, complete: 38% | | No significant effects
| | Tetraplegia, incomplete: 16%
| | Study duration: 16 months (mean)
Chen, 2006^72^ | Weight management program consisting of 12 classes for 12 weeks, primarily led by registered dietician. Classes covered nutrition, exercise, and behavior modification. Dietary approach utilized a time-calorie displacement diet. | 16 overweight (BMI ≥25) subjects, Male 56% (n=9), female 44% (n=7) | A. TGB. LDLC. HDL | [underlined: Mean change from baseline during program intervention (week 12) (mg/dl)].
Single group uncontrolled trial | | Mean age 44: (range 21–66) | | A TG -5.8±20.9 (baseline 201.7±30.2), p = 0.28; B LDL -1.8±22.1 (baseline 136.2±20.5), p = 0.76; C HDL -3.2±5.4 (baseline 43.1±14.9), p = 0.03
| | White: 81% (n=13) | | [underlined: Mean change from baseline during postintervention followup (week 24) (mg/dl)].
| | African American: 19% (n=3) | | A TG 0.3±24.1, p = 0.96; B LDL -4.2±18.1, p = 0.42; C HDL -0.9±5.4, p = 0.59
| | Mean duration since injury: 17.5 Years since injury (15) or illness (1)
| | Study duration: 12 weeks and 24 weeks
B. Pharmacologic therapy
No studies reporting

One controlled clinical trial compared the effect of a dietary intervention referral compared to no dietary referral over a mean of 16 months.^20^ Overall, mean age was 38.5 years and 89 percent were male. All subjects must have had an SCI of at least two years in duration. Group 1 (n=86) received a dietary intervention referral based on the recommendations of the American Heart Association and American Dietetic Association Guidelines. These subjects had a total cholesterol level greater than 200 mg/dL. Group 2 (n=136) received no dietary intervention referral. All subjects had a total cholesterol level ≤200 mg/dL. Group 1 subjects were significantly older (mean 42.8 versus 35.7, p <0.0001) and had a longer post-injury duration (15.6 versus 11.1 years, p <0.0001) compared to Group 2 subjects. Dietary intervention was effective in reducing some lipid parameters. There were significant reductions in total and low density lipoprotein cholesterol levels from baseline in Group 1, 234 to 224 (p <0.001) and 159 to 151 (p = 0.004), respectively. Levels increased slightly but not significantly in Group 2. In Group 1, 67 percent had decreases in LDL-C compared to 47 percent in Group 2 (p = 0.007). Secondary analysis found 15 percent had reductions ranging from 30 to 69 mg/dL and the LDL-C values declined from greater than 135 mg/dL to <135 mg/dL in 21 percent. There were no significant effects on high density lipoprotein cholesterol or triglyceride levels in either group.

The second uncontrolled pilot study evaluated a weight management program consisting of 12 classes for 12 weeks, primarily led by a registered dietician.^72^ Classes covered nutrition, exercise, and behavior modification. The dietary approach utilized a time-calorie displacement diet. The study followed 16 overweight subjects (BMI ≥25), up to 24 weeks. Subjects were on average 44 years of age, nine were men, 13 were White, and three were African American. There were no significant changes in total and LDL cholesterol levels from baseline at weeks 12 and 24. At week 12, TCl was reduced by 5.8 mg/dL (p = 0.28) and LDL cholesterol by 1.8 mg/dL (p = 0.76). By week 24, the mean changes were 0.3 mg/dL (p = 0.96) and -4.2 mg/dL (p = 0.42), respectively. HDL cholesterol was reduced significantly by 3.2 mg/dL from a baseline value of 43.1 mg/dL (p = 0.03) at week 12 and -0.9 mg/dL (p = 0.59) by week 24.