# Methods

## Topic Assessment and Refinement and Literature Review

A Technical Expert Panel (TEP) was convened, comprised of individuals with expertise in rehabilitation/physical therapy/neuromuscular aspects of chronic SCI, primary care relevant to patients with chronic SCI, lipid and carbohydrate disorders, dietary intervention, exercise, and pharmacotherapy in patients with chronic SCI. Names of individuals who agreed to participate, their CVs, and disclosure statements were sent to the Agency for Healthcare Research and Quality (AHRQ) for review and approval by the end of January 2007. Those members are identified in Appendix A.

Based on discussions with our partner and TEP members, we developed inclusion and exclusion criteria for study design and size, population, intervention, comparator groups, and outcomes. Question 2 was refined to read:

- What is cardiovascular prevalence and mortality in adults with chronic posttraumatic spinal cord injuries?
- Does cardiovascular prevalence and mortality in adults with chronic posttraumatic spinal cord injuries differ compared to the general population based on age, race, and gender categories?
- What is the strength of the association between cardiovascular prevalence and mortality and abnormalities in lipid and glucose metabolism including Type 2 diabetes mellitus, after adjustment for possible confounding factors?
- Does association vary depending on age, gender, race, the duration after SCI, the level of SCI, and functional impairment?

We evaluated, but ultimately did not include, findings from systematic reviews of randomized controlled trials (RCTs) related to behavioral, dietary or pharmacologic interventions as primary prevention of CVD and carbohydrate and lipid disorders in able-bodied adults. The rationale was that little RCT evidence regarding the efficacy and harms of these interventions in SCI individuals existed. It was unlikely that outcomes from these interventions would markedly differ between SCI and able-bodied individuals. Therefore, findings from these intervention studies in able-bodied controls were used to assess baseline lipid and carbohydrate characteristics as well as effectiveness and harms in able-bodied individuals. We also sought to determine whether evidence from these RCTs or current practice guidelines suggested that thresholds for diagnosis or intervention in SCI individuals currently recommended for able-bodied adults should be altered for SCI individuals.

Following the initial conference calls, the Minnesota Evidence-based Practice Center (EPC) conducted a systematic review and meta-analysis (where feasible) of published evidence of the association between lipid and carbohydrate disorders and risk of cardiovascular diseases in adults with chronic SCI. The prevalence of insulin resistance, metabolic syndrome, diabetes mellitus, impaired glucose tolerance, obesity, and abnormalities in lipid metabolism in patients with chronic SCI was estimated from cross-sectional studies that attempted to capture a nationally representative sample of adults with SCI. Observational cohort and case-control studies that tested the hypothesis of the association between carbohydrate and lipid disorders and risk of CVDs in adults with chronic SCI were reviewed. The risk of CVDs among patients with chronic SCI was analyzed. We examined case control and cohort studies to determine if risks of carbohydrate and lipid disorders and CVDs are greater in adults with SCI than in age/gender matched controls without SCI.

The role of different forms of exercise (passive and active, person initiated, and due to electrical stimulation) and diet in the prevention and treatment of carbohydrate and lipid disorders and corresponding sequelae in adults with chronic SCI was evaluated from observational studies and clinical trials. Controlled and randomized trials that examined the effects of exercise, diet, and pharmacological intervention on cardiovascular risk and outcomes in adults with chronic SCI were analyzed. Our preliminary search found few controlled trials of these interventions and only one survey report that assessed their impact on major cardiovascular endpoints, such as morbidity and mortality. Therefore, we estimated the potential impact of early detection and treatment of adults with SCI by evaluating large RCT and systematic reviews of treatments for lipid and carbohydrate disorders in adults without SCI. Our comprehensive work plan covered the assessment and refinement of study questions, proposed literature search and review, inclusion/exclusion criteria, and methods for evaluating the quality of studies and rating the strength of evidence.

The following conceptual model (Figure 1) was created:

Figure 1. Conceptual model. Contribution of carbohydrate and lipid disorders to risk of cardiovascular disease in adults with chronic posttraumatic SCI

Adapted from American College of Endocrinology statement on insulin resistance^4^

Bold - eligible outcomes

### Literature Search Strategy and Eligibility Criteria

The search strategy is presented in Appendix B. The general approach is described below. Specific items for each question are based on conference calls with our TEP members.

Question 1. A literature search was conducted on Ovid MEDLINE^®^, using the search term spinal cord injury combined with the following terms: hyperinsulinemia or hyperinsulinism or insulin resistance or Metabolic Syndrome X or metabolic syndrome; diabetes mellitus or glucose intolerance or impaired glucose tolerance; hyperlipidemias or HDL cholesterol or low HDL cholesterol; and obesity. The search was limited to articles published from 1990 to May 2007 or to articles recommended by peer reviewers through October 2007.

Studies were included if:

1 Adults had chronic SCI, defined as 1 year or more since sustaining the injury;
2 The total number of spinal cord subjects was at least 100, or totaled at least 100 subjects if a control group was included;
3 Reported outcomes such as the prevalence of obesity, diabetes, impaired glucose tolerance, metabolic syndrome or insulin resistance, or lipid disorders or reported mean BMI or lipid levels (total cholesterol, HDL cholesterol, LDL cholesterol, or triglycerides);
4 Were published in the English language. For able-bodied individuals we used nationally representative samples from NHANES that reported on obesity, diabetes and glucose intolerance, and lipid disorders. In particular, we were interested in results provided according to age categories and male gender because nearly 90 percent of reported SCI individuals were male. We also included a single uncontrolled study of 93 SCI adults that assessed insulin resistance and metabolic syndrome because only one other report for insulin resistance and no studies for metabolic syndrome met our predefined eligibility criteria.

Question 2. Original epidemiologic investigations of more than 50 patients with traumatic chronic (>1 year after injury) SCI published in English after 1990 were identified in MEDLINE^®^ via PubMed^®^. The search of the Cochrane library and the websites including the American Spinal Injury Association, American Paraplegia Society, Paralyzed Veterans of America, Consortium of Spinal Cord Medicine, and the catalog WorldCat identified reviews but not additional original studies.

Question 3a (exercise). The Endnote library containing original and review articles (n=2,212) was searched for abstracts that included the words fitness, physical activity, or exercise, resulting in a subset of 304 citations. In addition, a University of Minnesota medical reference librarian assisted in a MEDLINE^®^ search in response to the question, “What is the role of exercise in the prevention/treatment of carbohydrate and lipid metabolism disorders in people with spinal cord injury or disease?” This search, limited to human studies written in English and published between 1996 and 2007, resulted in 13 original articles as well as one review article. Of these, one relevant original article^65^ and the review article^85^ were not previously identified in the Endnote library. The original article was added to the database, for a total of 305 citations.

Question 3b. To identify and evaluate evidence whether pharmacologic or dietary interventions play a role in the prevention and/or treatment of carbohydrate and lipid metabolism disorders in the SCI population, studies were identified by searching in MEDLINE^®^ through May 2007 or by recommendations of peer reviewers through October 2007. Our initial literature search used the same search string utilized for Question 1. In addition, reference lists of relevant studies or reviews were also searched. Since no randomized trials were identified, nonrandomized (controlled or uncontrolled) studies were eligible. To be included, studies had to:

1 Evaluate adults who had chronic SCI, defined as one year or more since sustaining the injury;
2 Evaluate pharmacologic or dietary interventions;
3 Report carbohydrate and/or lipid related outcome measures;
4 Be published in the English language.

To address question 3b regarding the effectiveness of interventions on carbohydrate and lipid disorders to prevent CVD outcomes and mortality and diabetes in able-bodied adults, we relied on RCTs or systematic reviews of RCTs. Studies were identified using the Cochrane Library and searching MEDLINE^®^ through September 2007. The search was limited to the English language. Included studies must have enrolled or evaluated separately able-bodied adult subjects without pre-existing CVD or Type 2 diabetes and reported clinical outcomes such as mortality, myocardial infarction, stroke, or prevalence of Type 2 diabetes. Studies reporting only improvements in lipid or glucose values were excluded. To limit the scope of the therapeutic interventions, we evaluated primarily clinically proven pharmacologic interventions, with the exception of omega-III fatty acids. Results were assessed and summarized but not formally included in the final report (they are available from the authors upon request).

### Data Synthesis

For Questions 1 and 2 related to prevalence, we extracted the percentage of individuals with a diagnosis of diabetes, impaired glucose tolerance, insulin resistance, lipid abnormality, obesity (including BMI categories), CVD, and mortality according to the definitions provided to the authors. Additionally, we extracted mean carbohydrate, lipid, or BMI values. We pooled values to estimate the mean total, LDL, HDL cholesterol, and triglyceride (TG) values as well as BMI for adults with SCI and displayed these in comparison to a representative sample of U.S. adults from NHANES. Where data were available we used age stratified NHANES values for U.S. males because nearly 90 percent of SCI subjects were male with mean ages between approximately 30 and 60. We used a random-effects model to estimate the weighted mean difference with 95 percent confidence intervals (CI) in lipid values between SCI adults and able-bodied controls.

For Question 2, the results of individual studies were abstracted (see Appendix C for abstraction form) and summarized in evidence tables to analyze the level of evidence, differences in populations and definitions of the outcomes, and the association between risk factors with cardiovascular prevalence and mortality by age and injury status. We analyzed outcomes using the exact definitions from the individual studies. Any combinations were possible only for the same International Classification of Diseases (ICD) codes. Prevalence was calculated as the number of CVD events among the total number of SCI patients in the study; standard error and CI for population prevalence were calculated with Wilson estimate.^95^ We calculated mortality as a proportion of the patients who died from CVDs during the time of the data collection among the total sample of SCI patients. We could not analyze annual mortality rates because the authors did not report this outcome. We calculated crude odds ratios (OR) of the outcomes when the author reported rates in SCI patients and able-bodied controls.^96^ Meta-analysis was used to assess the pooled prevalence of CVD with random effects models.^97^ Assumptions underlying meta-analysis included valid measurements of the outcomes and similarity in study and target populations. Chi squared tests and I squared tests were used to assess heterogeneity in study results.^98^–^100^ Calculations were performed using STATA software.^101^

For Question 3, we extracted and reported the individual study outcome results with tests of significance for SCI patients as reported by authors. Variation in study design, population, intervention, and outcome did not permit pooling.

### Strength of Evidence

The strength of the available evidence was rated according to methods of the U.S. Preventive Services Task Force via a three-point scale (high, medium, and low). Confidence in the level of evidence from the review of assessing interventions in able-bodied adults is considered high based on the consistent results from at least two high-quality studies with long-term followup. For all other questions strength is considered low due to serious flaws in study design, inconsistency in findings, and subsequent risk of bias in outcome assessment.