# Introduction

## Overview

Spinal cord injuries (SCI) result in 11,000 hospitalizations of new cases annually in the United States.^5,^ ^6^ More than 240,000 Americans live with a disability related to SCI and the estimated annual cost averages $9.7 billion.^5,^ ^7,^ ^8^ Improved quality of care over the last several decades has resulted in a 40 percent decline in mortality during the two years following the injury.^9^ However, improvement in long-term survival has been smaller. Cardiovascular diseases (CVD) have been reported as the most common cause of death in adults with chronic SCI.^2,^ ^10^–^12^ CVD risk factors associated with SCI include behavior (smoking, limited exercise) and metabolic abnormalities (obesity, metabolic syndrome,^13^–^15^ and diabetes^11^). The prevalence of dyslipidemia^16,^ ^17^ and coronary heart disease has been reported to be higher in adults with SCI compared to the general population.^10,^ ^18^ The Institute of Medicine recently released two reports that emphasized the role of cardiovascular risk assessment and management in adults with chronic SCI.^6,^ ^11^ Some evidence suggests that exercise,^19^ diet,^20,^ ^21^ and pharmacological therapy^22^ may reduce diabetes and cardiovascular disease risk in these individuals. Furthermore, markers or thresholds of carbohydrate and lipid disorders commonly used in adults without SCI may not apply to the population that has sustained SCI. In particular, because adults with SCI lose muscle mass that is replaced with fat mass, traditional measure of obesity (weight or body mass index [BMI]) may not be appropriate.

Accurate estimates of diabetes prevalence and severity in adults with SCI may:

1 be underestimated relative to able-bodied controls because individuals with SCI may not undergo regular testing,
2 have lower levels of high-density lipoprotein (HDL) cholesterol that go unrecognized if providers only assess total cholesterol (TC) levels or base treatment solely on low-density lipoprotein (LDL) cholesterol, or
3 they have earlier evidence of impaired glucose tolerance or altered insulin sensitivity. Existing guidelines do not include routine evaluation of glucose and lipid abnormalities nor do they provide recommendations for threshold definitions of abnormality or target levels for interventions to achieve.^23^–^25^ Furthermore, the prevalence, morbidity, and mortality associated with carbohydrate and lipid disorders may differ in adults with SCI compared to able-bodied individuals.

Effective interventions to treat carbohydrate and lipid disorders and reduce cardiovascular complications in able-bodied individuals include dietary, pharmacologic, and exercise therapies. However, adults with SCI have unique physiologic characteristics that may preclude generalization of evidence from able-bodied individuals to those with SCI. Total daily energy expenditure for adults with SCI is difficult to calculate but likely much lower than for able-bodied individuals, especially among individuals requiring motorized wheelchairs for mobility. Treatment of obesity in SCI remains largely empiric, including guidelines developed for dietary intervention in SCI. Pharmacologic therapies to alter carbohydrate and lipid disorders may have different effectiveness and adverse effects in individuals with SCI compared to able-bodied patients. For example, assessment of hepatic or muscle toxicity in SCI individuals may be difficult using traditional serologic measures developed in able-bodied adults because SCI individuals have reduced muscle mass and potentially altered hepatic metabolism.

Despite the expected benefits of exercise for individuals with SCI, this group also faces unique challenges and risks from exercise that are not experienced by the able-bodied population.^8,^ ^26^ For one, lack of access to and choices in exercise modes, depending on the neurological impact and level of the injury, form physical barriers to obtaining exercise. Physiological risks of exercise are also a barrier to improved fitness among those with SCI. Depending on the level and completeness of the spinal injury, motor, sensory, and autonomic reflexes may still be intact but no longer under control of the brain. Individuals with SCI also experience various types of autonomic and circulatory dysregulation.^26^ Risk of stress-related musculoskeletal injury is of concern, given the reliance on a small group of muscles for activities of daily living as well as for any physical conditioning. Fractures, joint dislocation, and overuse injuries are common for individuals with SCI.^27^

In selected highly motivated able-bodied population, exercise, and its resulting improvements in aerobic capacity, appear to modestly improve carbohydrate metabolism, lipid profiles, and general cardiovascular health.^7,^ ^87^–^90^ For example, even moderate levels of physical activity, defined as three to six metabolic equivalents (METs) sustained for 30 minutes five to six times per week, may reduce the risk of cardiovascular disease and all-cause mortality.^91^ Current Centers for Disease Control and Prevention (CDC) and American College of Sports Medicine recommendations for exercise in the able-bodied population include 30 minutes of moderate physical activity, five to six times per week, or 20 minutes of vigorous (greater than six METs) physical activity, three or more times per week.^92^

However, translation of these findings to community settings of SCI adults has not been demonstrated, and even the effectiveness in the general able-bodied population is unclear. For example, a recent randomized trial evaluated the effects of 22 weeks of aerobic training, resistance training, or both (three times per week) on glycemic control in 251 able-bodied adults with Type 2 diabetes.^86^ Combined training resulted in a 1 percent absolute reduction in glycated hemoglobin values vs. sedentary controls. Reductions due to either resistance or aerobic training alone were about one-half that seen with combination therapy. There was no difference in lipid values, blood pressure, lean body mass, fat mass, or percent body fat of any of the exercise programs vs. controls. Adverse events were more common in the exercise group and 14 percent of those randomized to exercise dropped out.

Whether this amount of physical activity would produce the same benefits in patients with SCI is unknown. However, it is reasonable to assume that similar metabolic responses to exercise would occur for these individuals. No evidence-based guidelines for exercise in this population currently exist.^93^ At present, the American College of Sports Medicine's endurance training recommendations for those with SCI are relatively similar to advice directed toward the general population. Generally, the recommended exercise prescription, at least for those with paraplegia, is three to five weekly sessions of 20 to 60 minutes in duration and at an intensity of 50 to 80 percent of the individual's peak heart rate.^94^ Suggested modes of exercise include arm cranking, wheelchair propulsion, swimming, wheelchair sports, circuit resistance training, electrically-stimulated cycling, and electrically-stimulated walking.

Based on a topic and key questions nominated by the Consortium for Spinal Cord Medicine, we conducted a systematic review of published evidence to address the following questions:

Question 1a: What proportion of adult patients with chronic posttraumatic spinal cord injuries have been diagnosed with:

a Insulin resistance syndrome, metabolic syndrome
b Diabetes mellitus Type 2, impaired glucose tolerance
c Dyslipidemia
d Obesity

Question 1b: Is the prevalence of carbohydrate and lipid disorders higher in the subgroups of patients by age, race, and gender compared to the general population? Does the prevalence of carbohydrate and lipid disorders differ by the time after trauma, the level of trauma, and functional impairment?

Question 2: For people with SCI, what is the evidence on contribution to risk of cardiovascular disease of:

a Hyperinsulinemia
b Abnormalities in carbohydrate metabolism
c Abnormalities in lipid metabolism?
d Obesity

This question was refined as:

Question 2: Regarding risk of cardiovascular disease for people with SCI:

a What is cardiovascular prevalence and mortality in adults with chronic posttraumatic spinal cord injuries?
b Does cardiovascular incidence and mortality in adults with chronic posttraumatic spinal cord injuries differ compared to the general population based on age, race, and gender categories?
c What is the strength of the association between cardiovascular incidence and mortality and abnormalities in lipid and glucose metabolism including Type 2 diabetes mellitus after adjustment for possible confounding factors?
d Does association vary depending on age, gender, race, the duration after SCI, the level of SCI, and functional impairment?

Question 3: What are the effects on carbohydrate or lipid-related outcomes in adults with SCI of:

a Exercise
b Dietary and pharmacologic interventions