# Appendix E: Evidence Tables

Table 1 Prevalence of metabolic syndromes, diabetes, glucose, lipid abnormalities, and BMI in adults with chronic posttraumatic SCI

Reference | Study Design | Subject Characteristics | Prevalence
Prevalence of metabolic syndrome and insulin resistance in people with SCI and disease
Lee, 2005^1^ | Convenience sample of 93 SCI patients from a Veterans Affairs hospital and local community. All were diagnosed for lipid panel, insulin, and glucose values. | Male: 86.0% (n=80) | [underlined: Metabolic syndrome and insulin resistance]
| USA | Female: 14.0% (n=13) | 22.6% (21 of 93 subjects)
| | Paraplegia: 58.1% (n=54)
| | Tetraplegia: 41.9% (n=39)
Bauman, 1999^2^ | Cross-sectional study including a convenience sample of 201 SCI patients from a single clinical center who had oral glucose tolerance tests. Patients were subgrouped by level of injury. | Mean age (years): 39 | Hyperinsulinemia
| USA | Male: 84% (n=169) | Tetraplegia group 53% (n=43)
| | Female: 16% (n=32) | Paraplegia group 37% (n=44)
| | White: 27% (n=54) | P <0.05
| | Latino: 57% (n=114)
| | African American: 14% (n=28)
| | BMI: 25
| | Injury:
| | Mean duration of SCI (years): 13
| | Mean age at injury: 25
| | Tetra complete: 28% (n=56)
| | Tetra incomplete: 12% (n=25)
| | Para complete: 42% (n=84)
| | Para incomplete: 18% (n=36)
Prevalence of diabetes in people with SCI and disease
Bauman, 1999^2^ | Cross-sectional study including a convenience sample of 201 SCI patients from a single clinical center who had oral glucose tolerance tests. Patients were subgrouped by level of injury. | Mean age (years): 39 | Diabetes: 13.4% (n=27)
| USA | Male: 84% (n=169) | [underlined: Results from fasting glucose testing:]
| | Female: 16% (n=32) | Overall diabetes: 3% (n=7)
| | White: 27% (n=54) | Tetraplegia complete: 4% (n=2)
| | Latino: 57% (n=114) | Tetraplegia incomplete: 0% (n=0)
| | African American: 14% (n=28) | Paraplegia complete: 1% (n=1)
| | BMI: 25 | Paraplegia incomplete: 11% (n=4)
| | Injury: | [underlined: Results from 2 hour glucose challenge testing:]
| | Mean duration of SCI (years): 13 | Overall diabetes: 13% (n=27)
| | Mean age at injury: 25 | Tetraplegia complete: 23% (n=13)
| | Tetra complete: 28% (n=56) | Tetraplegia incomplete: 16% (n=4)
| | Tetra incomplete: 12% (n=25) | Paraplegia complete: 6% (n=5)
| | Para complete: 42% (n=84) | Paraplegia incomplete: 11% (n=4)
| | Para incomplete: 18% (n=36).
Lavela, 2006^3^ | National cross-sectional survey of 3,737 Veterans Affairs SCI subjects. | Veterans with SCI subgroups | [underlined: Diabetes prevalence]
| USA | 1. Veterans with spinal disease (VSD) | VSD 20.0%; GVP 21.0%; GP 7.6%*
| | A. With diabetes (n=741) | *p <0.0001, VSD vs. GP
| | Mean age (years): 64.1* | [underlined: Diabetes prevalence by comparison group by age]
| | Male: 98.2% (n=728) | Age (years)
| | White: 76.6% (n=568) | <40: VSD 4.6%; GVP 3.9%; GP 1.9%
| | Nonwhite: 23.4% (n=173)* | 40–44: VSD 6.7%; GVP 13.7%; GP 5.0%
| | Mean duration of SCI (years): 23.9 | 45–49: VSD 10.2%; GVP 8.0%; GP 6.7%
| | Paraplegia: 67.3% (n=499)* | 50–54: VSD 17.5%; GVP 16.2%; GP 9.4%
| | Tetraplegia: 32.7% (n=242) | 55–59: VSD 20.2%; GVP 18.7%; GP 13.0%
| | Mean age at injury: 40.0* | 60–64: VSD 23.1%; GVP 35.2%; GP 16.0%
| | B. Without diabetes (n=2,967) | 65–69: VSD 24.9%; GVP 28.6%; GP 15.7%
| | Mean age (years): 59.2 | 70+: VSD 26.2%; GVP 24.0%; GP 15.6%
| | Male: 96.8% (n=2,872) | [underlined: Duration of diabetes: comparison of groups]
| | White: 82.7% (n=2,454) | VSD n=741; GVP n=1,342; GP n=16,676
| | Nonwhite: 17.3% (n=513) | Mean duration (years): VSD 25.5; GVP 10.7; GP 9.7
| | Mean duration of SCI (years): 23.8 | Duration >25 years: VSD 13.6%*; GVP 10.9%; GP 9.8%
| | Paraplegia: 61.6% (n=1,828) | *p ≤0.01, VSD vs. GP
| | Tetraplegia: 38.4% (n=1,139) | [underlined: Risk for clinical conditions, SCI veterans with diabetes compared to SCI veterans without diabetes]
| | Mean age at injury: 35.4 | A. Coronary Heart Disease (n=3,177)
| | * p=0.000, A vs. B | Percent in SCI/D group: 12%; OR 2.8 [95% CI 2.2 to 3.6].
| | 2. GVP = General Veteran Population (n=6,413) | B. Myocardial infarction (n=3,230)
| | 3. GP = General Population, from Centers for Disease Control Behavioral Risk Factor Surveillance System 2003 survey data (n=221,650) | Percent in SCI/D group: 14%; OR 2.9 [95% CI 2.1 to 3.4].
| | | C. High cholesterol (n=3,415)
| | | Percent in SCI/D group: 48%; OR 2.5 [95% CI 2.1 to 3.0].
| | | D. Stroke (n=3,170)
| | | Percent in SCI/D group: 8%; OR 2.3 [95% CI 1.7 to 3.0].
| | | E. Hypertension (n=3,438)
| | | Percent in SCI/D group: 49%; OR 2.5 [95% CI 2.1 to 3.0]
Frisbie, 2005^4^ | Chart review of 166 Veterans Affairs patients admitted for SCI rehabilitation within 108 days of paralysis using discharge diagnosis. | Veterans with SCI subgroups | [underlined: Diabetes prevalence by comparison group by age at the time of acute SCI]
| Patients ≥40 years at time of injury (n=87) were followed for five years. | A. Age <40 years at time of injury (n=79) | Age (years)
| USA | Mean age (years): 27 | 16–39: 0% (n=79)
| | Male: 94.9% (n=75) | ≥40: 21% (18 of 87 subjects)
| | SCI, cervical: 56% (n=44) | [underlined: Diabetes prevalence at 5-year followup in patients ≥40 years at time of SCI]
| | Complete motor: 72% (n=56) | 20% (13 of 64* subjects)
| | A. Age ≥40 years at time of injury (n=87) | *excludes subjects lost to death and followup. Three subjects in non-diabetic subgroup developed diabetes.
| | Mean age (years): 60 | [underlined: 5-year mortality in patients ≥40 years]
| | Male: 97.7% (n=85) | Diabetic subgroup (n=17, one lost to followup): 7 deaths; mortality rate 41%*
| | SCI, cervical: 67% (n=58) | Non-diabetic subgroup (n=64, 5 lost to followup): 10 deaths; mortality rate 16%.
| | Complete motor: 43% (n=37) | p=0.04 between groups
| | B subgroups
| | B^1^. Diabetic subgroup n=18 (21%) (all males)
| | Mean age: 66
| | SCI, cervical: 72% (n=13)
| | Complete motor: 33% (n=6)
| | B^2^. Non-diabetic subgroup n=69 (79%)
| | Mean age: 59
| | SCI, cervical: 65% (n=45)
| | Complete motor: 45% (n=31)
| | Inclusion: treatment for DM; 2 fasting blood glucose levels >140mg%, a single random glucose of >200mg%, or a single hemoglobin A1C >7mg%
| | Exclusion: DM was rejected if related to administration of corticosteroids
Garshick, 2005^5^ | A prospective mortality study of 361 SCI males injured ≥1 year | A. Survivors (n=324) | [underlined: Diabetes prevalence 10.0%]
| | Mean age (years): 48.9 | A. Survivors (n=324) 8.3% (n=27)
| | White: 93.2% (n=302) | B. Deceased subjects (n=37) 24.3% (n=9)
| | Nonwhite: 6.8% (n=22) | [underlined: Observed/expected deaths] 2.0/0.53
| | BMI: 26.3 | [underlined: Standardized mortality ratio] 3.74 [95%CI 0.45 to 13.51]
| | Age at SCI: 32.2
| | Mean duration of SCI (years): 16.7
| | Level of Injury
| | Complete cervical: 21.3% (n=69)
| | T1–T4: 14.8% (n=48)
| | T5–T12: 12.4% (n=40)
| | Others: 10.8% (n=35)
| | Incomplete
| | Cervical ASIA C: 10.8% (n=35)
| | Cervical ASIA D: 12.4% (n=40)
| | Other ASIA C: 7.7% (n=25)
| | Other ASIA D: 9.9% (n=32)
| | B. Deceased (n=37)
| | Mean age (years): 65.0
| | White: 94.6% (n=35)
| | Nonwhite: 5.4% (n=2)
| | BMI: 26.0
| | Age at SCI: 40.8
| | Mean duration of SCI (years): 24.2
| | Level of Injury
| | Complete cervical: 16.2% (n=6)
| | T1–T4: 10.8% (n=4)
| | T5–T12: 18.9% (n=7)
| | Others: 8.1% (n=3)
| | Incomplete
| | Cervical ASIA C: 16.2% (n=6)
| | Cervical ASIA D: 5.4% (n=2)
| | Other ASIA C: 16.2% (n=6)
| | Other ASIA D: 8.1% (n=3)
Lee, 2005^1^ | Convenience sample of 93 SCI patients from a Veterans Affairs hospital and local community. All were diagnosed for lipid panel, insulin, and glucose values. | Male: 86.0% (n=80) | [underlined: Diabetes prevalence]
| USA | Female: 14.0% (n=13) | 21.3% (20 of 93 subjects)
| | Paraplegia: 58.1% (n=54)
| | Tetraplegia: 41.9% (n=39)
Prakash, 2002^6^ | Population:26,734 able-bodied male veterans and 654 patients with spinal cord injuries | A. SCI (n=654) | [underlined: Diabetes prevalence]
| 47,070 patients with at least one ECG obtained in the Palo Alto Veterans Affairs Health Care System. | Mean age: 50 | A. SCI: 11.0% (72 of 654 subjects)
| Retrospective cohort to examine prevalence of ECG abnormalities in individuals with spinal cord injuries. | Annual mortality: 2.6% | B. Able-bodied controls: 10.0% (2,673 of 26,734 subjects)
| | Duration of followup: 8 years
| | Hypertension: 7% (p<0.001 vs. B)
| | Congestive heart failure: 1.7% (p<0.001 vs. B)
| | Coronary artery disease: 1.7% (p<0.001 vs. B)
| | Pulmonary disease: 4.8% (p=0.01 vs. B)
| | B. Able-bodied controls (n=26,734)
| | Mean age: 56
| | Annual mortality: 3.0%
| | Duration of followup: 8 years
| | Hypertension: 44.0%
| | Congestive heart failure: 7.0%
| | Coronary artery disease: 7.0%
| | Pulmonary disease: 5.5%
| | Exclusion criteria: inpatient setting or emergency room at the time of ECG.
Imai, 1996^7^ | Questionnaire of 244 male SCI patients at 8 rehabilitation centers compared to general population. | Mean age: 47.6 (range: 22–69) | [underlined: Comparison of diabetes prevalence between SCI patients and the general population, Outpatient rate per 1,000 population]
| Japan | Mean duration of SCI: 17.3 | SCI: 61.5
| Likely same cohort as Imai 1994)^8^ | Site of injury subgroups: | General population: 12.2
| | A. Cervical (C) Thoracic (T) 5: 11.0% (n=23) | [underlined: Comparison of diabetes prevalence by SCI site of injury subgroup, Outpatient rate per 1,000 population]
| | B. T6–T10: 12.0% (n=30) | A. C-T5: 0.0
| | C. T11-Lumbar (L) 1: 69.0% (n=173) | B. T6–T10: 28 (extracted from graph)
| | D. L2-or below: 8.0% (n=18) | C. T11-L1: 62
| | Incomplete motor: 4.1% (n=10, 5 cervical and 5 thoracolumbar) | D. E. L2-or below: 165
McGlinchey-Berroth, 1995^9^ | Cross-sectional analysis of hospitalizations among 534 patients with SCI admitted to the high quality Spinal Cord Injury Service of the VA medical center (part of the Aging with a Long-Term Disability Research Program database). | Mean age: 50 (range 16–84) | [underlined: Diabetes prevalence] 9.8% (47 of 480 subjects)
| 510 discharged from the hospitals were included in the analysis. | Mean duration of SCI: 16 | A. Group 1 (N=225) 3.9%
| | Male: 99.0%. | B. Group 2 (N=162) 12.3%
| | Group 1 (N=225) persons <50 years of age at the time of injury and <5 years at index submission. | C. Group 3 (N=93) 22.6%
| | Group 2 (N=162) <50 years of age at the time of injury but >50 years at the time of index admission.
| | Group 3 (N=93) persons >50 years of age at the time of injury.
| | Exclusion criteria: not available discharge summary; current hospitalization, transfer to the long term care facility.
Zhong, 1995^10^ | SCI men (Veterans Affairs patients) studied during annual physical exam. | 197 men with chronic SCI, 103 paraplegia and 94 tetraplegia | [underlined: Diabetes prevalence]
| USA | Mean age: 50 (21–77) | Diabetes: 18.3% (n=36)
| | Mean duration of SCI: 18 (1–49)
| | Mean BMI: 25 (15.8–47.8)
| | Exclusion criteria: No prior history of diabetes or gout
Bauman, 1994^11^ | Veteran SCI patients, matched for age and BMI were compared to veteran controls. | SCI (n=100) | [underlined: Diabetes prevalence]
| USA | A. Paraplegia 50.0% (n=50) | SCI: 22.0% (n=22)
| | Mean age: 51.2 | Control: 6.0% (n=3)
| | Mean BMI: 25.7 | [underlined: Comparison of mean fasting plasma glucose (mg/dL) among groups]
| | Mean duration of SCI: 19 | A. Paraplegia: Normal 91; IGT 97; Diabetes 99*
| | B. Tetraplegia 50.0% (n=50) | B. Tetraplegia: Normal 87; IGT 90; Diabetes 102*†
| | Mean age: 47.2 | C. Control: Normal 97; IGT 104; Diabetes 115*
| | Mean BMI: 24.6 | *p<0.05 versus Normal, † p<0.05 versus IGT
| | Mean duration of SCI: 17
| | Controls n=50
| | Mean age: 51 years
| | Mean BMI: 26.9
Imai, 1994^8^ | Survey of 195 SCI male patients in Japan | Mean age: 49.5 | [underlined: Prevalence of diabetes by level of injury]
| | Mean duration of SCI: 17.9 | All subjects: 5.6%
| | Site of injury subgroups: | C-T10: 0.0% (32 subjects)
| | C-T5: 9.7% (n=19) | T11-L2: 6.5% (9 of 139 subjects)
| | T6–T10: 12.3% (n=24) | L2-or below: 15.4 (2 of 13 subjects)
| | T11-L1: 71.3% (n=139) | [underlined: Outpatient rate per 1,000 population]
| | L2-or below: 6.7% (n=13) | T11-L2: 65
| | | L2-or below: 154
| | | [underlined: Standard outpatient morbidity ratio (general population = 100)]
| | | T11-L2: 326*
| | | L2-or below: 945*
| | | *p<0.01 versus general population
Charlifue, 1999^12^ | A longitudinal, cross-sectional study of 315 SCI patients | Mean age: 37.1 | [underlined: Prevalence of diabetes (baseline)]
| | Male: 80.3% (n=253) | Overall: 2.5% (8 of 315 subjects)
| | Mean duration of SCI: 9.3 | Paraplegia ABC: 3.4% (5 of 147 subjects)
| | Subgroups | Tetraplegia ABC: 1.5% (2 of 133 subjects)
| | A. Paraplegia ABC*: 46.7% (n=147) | All D: 2.9% (1 of 35 subjects)
| | Mean age: 37.2 | [underlined: Prevalence of diabetes (at 5 years)]
| | Male: 76.4% (n=112) | Overall: 3.8% (12 of 315 subjects)
| | Mean duration of SCI: 9.3 | Paraplegia ABC: 4.8% (7 of 147 subjects)
| | B. Tetraplegia ABC*: 42.2% (n=133) | Tetraplegia ABC: 3.0% (4 of 133 subjects)
| | Mean age: 35.9 | All D: 2.9% (1 of 35 subjects)
| | Male: 84.2 (n=112) | [underlined: Diagnosis of DM by age group (baseline)]
| | Mean duration of SCI: 9.5 | <30 years: 0.0% (n=82)
| | C. All D*: 11.1% (n=35) | 30–50 years: 2.1% (4 of 190 subjects)
| | Mean age: 40.6 | 50+ years: 9.3% (4 of 43 subjects)
| | Male: 82.9 (n=29) | [underlined: Diagnosis of DM by age group (at 5 years)]
| | Mean duration of SCI: 8.9 | <30 years: 0.0% (n=82)
| | ASIA Impairment Scale: A = complete, no function; B = incomplete, sensory only; C = incomplete, some sensory and motor function; and D = incomplete, useful motor function. | 30–50 years: 4.1% (8 of 190 subjects)
| | | 50 + years: 11.6% (5 of 43 subjects)
Rish, 1997^13^ | 230 Vietnam vets with SCI were reviewed for a 25 year followup | Mean age: 21.4 years with previous excellent health at baseline | Prevalence of diabetes: 29/230 (13%)
| USA | Site of injury:
| | C2-T1: 21.0% (n=48)
| | T2–T10: 31.0% (N=71)
| | T11-L1: 23.0% (n=52)
| | L2-sacrum: 14% (n=32)
| | No vertebral injury noted: 11.0% (n=27)
| | Paraplegia, complete: 47.0% (n=109)
| | Paraplegia, incomplete: 28.0% (n=64)
| | Tetraplegia, complete: 14.0% (n=31)
| | Tetraplegia, incomplete: 9.0% (n=21)
| | Not delineated: 2.0% (n=5)
Prevalence of glucose intolerance in people with SCI and disease
Zhong, 1995^10^ | SCI men (Veterans Affairs patients) studied during annual physical exam. | 197 men with chronic SCI, 103 paraplegia and 94 tetraplegia | [underlined: Impaired glucose tolerance prevalence]
| USA | Mean age: 50 years (21–77) | Impaired Glucose Tolerance: 29.4% (n=58)
| | Mean duration of SCI: 18 (1–49)
| | Mean BMI: 25 (15.8–47.8)
| | Exclusion criteria: No prior history of diabetes or gout
Bauman, 1994^11^ | Veteran SCI patients, matched for age and BMI were compared to veteran controls. | SCI (n=100) | [underlined: Impaired glucose tolerance prevalence]
| USA | A. Paraplegia 50.0% (n=50) | SCI: 34.0% (n=34)
| | Mean age: 51.2 | Controls: 12.0% (n=6)
| | Mean BMI: 25.7 | [underlined: Comparison of mean fasting plasma glucose (mg/dL) among groups]
| | Mean duration of SCI: 19 | A. Paraplegia: Normal 91; IGT 97; Diabetes 99*
| | B. Tetraplegia 50.0% (n=50) | B. Tetraplegia: Normal 87; IGT 90; Diabetes 102*†
| | Mean age: 47.2 | C. Control: Normal 97; IGT 104; Diabetes 115*
| | Mean BMI: 24.6 | *p<0.05 versus Normal, † p<0.05 versus IGT
| | Mean duration of SCI: 17
| | Controls n=50
| | Mean age: 51 years
| | Mean BMI: 26.9
Bauman, 1999^2^ | Cross-sectional study including a convenience sample of 201 SCI patients from a single clinical center who had oral glucose tolerance tests. Patients were subgrouped by level of injury. | Mean age (years): 39 | [underlined: Impaired glucose tolerance]: 27.9% (n=56)
| USA | Male: 84% (n=169) | Comparison of mean fasting serum glucose (FS Glu) in mg/dl, peak serum glucose (Pk Glu) in mg/dl, fasting plasma insulin (FP Ins) in microU/ml, peak plasma insulin (Pk Ins) in microU/ml among groups (p-value for 3 df F-statistic):
| | Female: 16% (n=32) | Tetra complete | FS Glu=97 | PK Glu=193 | FS Ins=10 | Pk Ins= 216
| | White: 27% (n=54) | Tetra incomplete | FS Glu=102 | Pk Glu=178 | FS Ins=10 | Pk Ins= 148
| | Latino: 57% (n=114) | Para complete | FS Glu=97 | Pk Glu=158 | FS Ins=9 | Pk Ins= 152
| | African American: 14% (n=28) | Para incomplete | FS Glu=106; | Pk Glu=158 | FS Ins=10 | Pk Ins= 144
| | BMI: 25 | P-value by groups | p <0.0001 | p <0.0001 | p <0.01 | p <0.005
| | Injury:
| | Mean duration of SCI (years): 13
| | Mean age at injury: 25
| | Tetra complete: 28% (n=56)
| | Tetra incomplete: 12% (n=25)
| | Para complete: 42% (n=84)
| | Para incomplete: 18% (n=36).
Mean lipid values in subjects with SCI and disease
Moussavi, 2001^14^ | A cross-sectional study of 189 community-dwelling SCI patients | Mean age (years): 43.1 (range 19.2–81.9) | [underlined: Mean serum lipid values]
| USA | Men: 76.7% (n=145) | Total cholesterol (TC): 195.9
| | Women: 23.3% (n=44) | Low Density Lipoprotein (LDL): 120.2
| | White: 59.3% (n=112) | High Density Lipoprotein (HDL): 46.2
| | African American: 22.2% (n=42) | Triglyceride (TG): 148.3
| | Hispanic: 17.5% (n=33) | [underlined: Mean lipids values by gender]
| | Other: 1.1% (n=2) | Male (n=138): TC 193.9; LDL 120.8; HDL 43.7; TG 148.6
| | Mean duration of SCI (years): 12.5 (0.5–47.0 | Female (n=41): TC 202.4; LDL 118.1; HDL 54.2; TG 147.2
| | Tetraplegia (A,B,C*): 41.3% | [underlined: Mean lipids values by race]
| | Paraplegia (A,B,C*): 39.2% | White (n=104): TC 194.9; LDL 117.9; HDL 45.9; TG 155.4
| | Tetraplegia or paraplegia, level D*: 19.6% | African American (n=41): TC 190.9; LDL 122.2; HDL 47.5; TG 106.8
| | *Based on American Spinal Injury Association Impairment Scale. (A) no function, (B) sensory only, (C) some sensory and motor preservation, (D) useful motor function, and (E) normal. | Hispanic American (n=32): TC 203.4; LDL 123.2; HDL 45.7; TG 177.4
Bauman, 1999^15^ | Cohort of outpatient SCI patients (n=320) seen for annual exam vs. able-bodied controls (n=303) matched by age and ethnicity | SCI subjects (n=320) | [underlined: Comparison of mean lipid values between groups]
| USA | Mean age: 41 (20–77) | TC: SCI 190; Control 207*
| | Male: 73% (n=234) | LDL: SCI 126; Control 137*
| | Female: 27% (n=86) | HDL: SCI 42; Control 47**
| | White: 47% (n=150) | TG: SCI 108; Control 118†
| | African American: 28% (n=90) | * p<0.0001 (between groups), ** p<0.0005, † p<0.05
| | Hispanic: 26% (n=83) | [underlined: Comparison of mean lipid values between genders]
| | Mean BMI: 25 (13.8–54.8) | A. Males: SCI n=233; Control n=244
| | Body fat: 36% (21.1–72.3) | TC: SCI 191; Control 209*
| | BMI ≥27.8: 28% | LDL: SCI 129; Control 139**
| | Mean duration of SCI: 15 (1–57) | HDL: SCI 39; Control 45*
| | Motor complete: 65.6% | TG: SCI 114; Control 126†
| | Motor incomplete: 34.4% | * p<0.0001, ** p<0.01, † p<0.0005
| | Sedentary able-bodied controls (n=303) | B. Females: SCI n=87; Control n=59
| | Mean age: 42 (21–75) | TC: SCI 188; Control 199
| | Male: 81.0% (n=245) | LDL: SCI 118; Control 129
| | Female: 16.0% (n=48) | HDL: SCI 51; Control 54
| | White: 56.0% (n=170) | TG: SCI 94; Control 82
| | African American: 29% (n=88) | [underlined: Comparison of mean lipid values among ethnicities]
| | Hispanic: 16.0% (n=48) | A. White: SCI n=149; Control n=169
| | Mean BMI: 29.9 (19.7–49.9) (p<0.0001 vs. SCI) | TC: SCI 187; Control 209*
| | Body fat: 31.0% (10.2–72.5) (p<0.0001 vs. SCI) | LDL: SCI 125; Control 138**
| | BMI ≥27.8: 64.0% (p<0.0001 vs. SCI) | HDL: SCI 41; Control 46*
| | | TG: SCI 105; Control 119†
| | | * p<0.0001, ** p<0.005, † p<0.01
| | | B. African American: SCI n=88; Control n=87
| | | TC: SCI 195; Control 204
| | | LDL: SCI 128; Control 133
| | | HDL: SCI 49; Control 51
| | | TG: SCI 91; Control 101
| | | C. Hispanic: SCI n=83; Control n=43
| | | TC: SCI 190; Control 209*
| | | LDL: SCI 126; Control 138**
| | | HDL: SCI 49; Control 51
| | | TG: SCI 91; Control 101
| | | * p<0.01, ** p<0.05
Bauman, 1998a^16^ | A cohort of 600 SCI patients was investigated for lipid profiles and by ethnicity subgroups in a SCI clinic over 24 months. | Mean age: 37.6 | [underlined: Overall Mean lipid values]
| USA | BMI: 25.0 | TC: 190
| | White race: 26.5% (n=159) | LDL: 124
| | Hispanic: 47.0% (n=282) | HDL: 42
| | African American: 26.5% (n=159) | TG: 122
| | Mean duration of SCI: 12.4 | [underlined: Mean lipid values between groups]
| | Tetraplegia, complete: 30.8% (n=185) | TC: White 190; Hispanic 190: African American (AA) 191
| | Tetraplegia, incomplete: 18.7% (n=112) | LDL: White 125; Hispanic 124: AA 125
| | Paraplegia, complete: 32.8% (n=197) | HDL: White 40; Hispanic 39: AA 47*
| | Paraplegia, incomplete: 17.7% (n=106) | TG: White 121; Hispanic 137: AA 96*
| | A. White (n=159) | * p<0.05 for African American versus White and Hispanic
| | Mean age: 41.4 | [underlined: Categorical Groupings by Ethnic Group]
| | BMI: 24.9 | 1. LDL (mg/mL)
| | Mean duration of SCI: 17.4 | <100: White 24.0%; Hispanic 27.0%: AA28.0%
| | A. White (n=159) | 100–130: White 38.0%; Hispanic 34.0%: AA 30.0%
| | Mean age: 41.4 | 131–160: White 24.0%; Hispanic 22.0%: AA 24.0%
| | BMI: 24.9 | ≥161: White 14.0%; Hispanic 17.0%: AA18.0%
| | Mean duration of SCI: 17.4 | 2. HDL (mg/mL)
| | B. Hispanic (n=282) | <30: White 19.0%; Hispanic 21.0%: AA 6.0%*
| | Mean age: 36.0 | 30–34: White 17.0%; Hispanic 15.0%: AA13.0%
| | BMI: 25.3 | 35–40: White 18.0%; Hispanic 24.0%: AA16.0%
| | Mean duration of SCI: 10.6 | >40: White 46.0%; Hispanic 40.0%: AA 65.0%*
| | C. African American (n=159) | * p<0.05 for African American versus White and Hispanic
| | Mean age: 36.6
| | BMI: 24.5
| | Mean duration of SCI: 10.6
Bauman, 1998b^17^ | A cohort of 541 SCI patients were investigated for lipid profiles and by neurological deficit subgroups over a period of 2 years in a SCI clinic in CA | A. Tetraplegia (n=247) | [underlined: Comparison of mean lipid profiles between groups and subgroups]
Same cohort as Bauman 1998a^16^ | USA | Mean age: 38 | A. Tetraplegia (n=247)
| | Male: 90.0% (n=222) | TC: 184; Complete 181; Incomplete 190
| | Female: 10.0% (n=25) | LDL: 121; Complete 122; Incomplete 190
| | White race: 35.0% (n=86) | HDL: 39; Complete 38; Incomplete 40
| | African American: 20.0% (n=49) | TG: 122; Complete 118; Incomplete 125
| | Hispanic: 45.0% (n=111) | B. Paraplegia (n=294)
| | Mean duration of SCI: 13 | TC: 198; Complete 205; Incomplete 196
| | Motor complete: 63.2% | LDL: 122; Complete 129; Incomplete 119
| | Motor incomplete: 36.8% | HDL: 45; Complete 47; Incomplete 44
| | B. Paraplegia (n=294) | TG: 129; Complete 132; Incomplete 128
| | Mean age: 37
| | Male: 84% (n=247)
| | Female: 16.0% (n=47)
| | White race: 17.0% (n=50)*
| | African American: 28.0% (n=82)
| | Hispanic: 55.0% (n=162)
| | Mean duration of SCI: 12
| | Motor complete: 70.1%
| | Motor incomplete: 29.9%
| | * p<0.01 between groups
Zhong, 1995^10^ | SCI men (Veterans Affairs patients) studied during annual physical exam | 197 men with chronic SCI, 103 paraplegia and 94 tetraplegia | [underlined: Mean lipid values in the study groups]
| USA | Mean age: 50 (21–77) | A. All SCI subjects
| | Mean duration of SCI: 18 (1–49) | TC: 188
| | Mean BMI: 25 (15.8–47.8) | LDL: 124
| | Exclusion criteria: No prior history of diabetes or gout | HDL: 39
| | | TG: 122
| | | B. Paraplegia (n=103) vs. Tetraplegia (n=94)
| | | TC: Paraplegia 191; Tetraplegia 185
| | | LDL: Paraplegia 125; Tetraplegia 123
| | | HDL: Paraplegia 38; Tetraplegia 39
| | | TG: Paraplegia 130; Tetraplegia 114
| | | [underlined: Mean lipid values between subgroups with normal and elevated insulin levels]
| | | A. Normal insulin levels (n=119)
| | | LDL: 123
| | | HDL: 39
| | | TG: 109
| | | B. Hyperinsulinemia (n=78)*
| | | LDL: 126
| | | HDL: 37
| | | TG: 143 (p=0.004 vs. normal insulin group)
| | | *Defined as peak plasma insulin >150ul/mL during oral glucose tolerance test (75g)
Bauman, 1992^18^ | Veteran SCI patients, matched for age and BMI, were compared to veteran controls | A. Paraplegia: n=50 | [underlined: Mean lipid values in the study groups]
| USA | Mean age (years): 49.5 | A. Paraplegia (n=50)
| | Mean BMI: 26.0 | TC: 191*
| | Mean duration of SCI: 17.6 | LDL: 124
| | B. Tetraplegia: n=50 | HDL: 37**
| | Mean age: 46.2 | TG: 148
| | Mean BMI: 24.0 | B. Tetraplegia (n=50)
| | Mean duration of SCI: 15.0 | TC: 188*
| | C. Controls: n=50 | LDL: 128
| | Mean age: 48.8 | HDL: 40**
| | Mean BMI: 26.8 | TG: 101†
| | | Controls (n=50)
| | | TC: 210
| | | LDL: 136
| | | HDL: 48
| | | TG: 134
| | | * p<0.01, ** p<0.0001, † p<0.05 across groups (ANOVA)
| | | [underlined: HDL cholesterol levels by SCI and subgroups]
| | | A. All SCI subjects (n=100)
| | | <30: 13.0% (n=13)
| | | 30–34: 24% (n=24)
| | | ≥35: 63.0% (n=63)
| | | B. Paraplegia (n=50)
| | | <30: 18.0% (n=9)
| | | 30–34: 22% (n=11)
| | | ≥35: 60.0% (n=30)
| | | B. Paraplegia (n=50)
| | | <30: 8.0% (n=4)
| | | 30–34: 26% (n=13)
| | | ≥35: 66.0% (n=33)
Krum, 1992^19^ | Risk factors for cardiovascular disease in 327 consecutive SCI patients, matched for age and sex, were compared to controls from the Australian population | Age range: 25–64 | [underlined: Total cholesterol levels by age in males]
| | Male: 84.0% (n=275) | All ages: SCI 208; Control 217(estimated from graph)
| | Female:16.0% (n=52) | Age 25–29: SCI 185; Control 198
| | Duration of SCI: 34% had SCI for more than 10 years | Age 30–34: SCI 197; Control 204
| | Control subjects (n not reported) | Age 35–39: SCI 216; Control 217
| | | Age 40–44: SCI 206; Control 214
| | | Age 45–49: SCI 216; Control 226
| | | Age 50–54: SCI 216; Control 227
| | | Age 55–59: SCI 209; Control 229
| | | Age 60–64: SCI 206; Control 232
| | | [underlined: Total cholesterol levels, female gender and duration of SCI]
| | | Female: SCI 190; Control 217
| | | SCI, >10 years: SCI 192
| | | [underlined: Total cholesterol levels by level of spinal lesion]
| | | Cervical: 188
| | | Low thoracic: 182
| | | High thoracic: 199
| | | Lumbar: 205
Prevalence of obesity and mean BMI categories in people with SCI and disease
Weaver, 2007^20^ | Observational, retrospective review of clinical and administrative data of 7,959 veterans with SCI/D (5% had injuries <1 year) | Mean age (years): 58.2 | [underlined: Mean BMI and categories]
| USA | Age ≥65 years: 35.0% (n=2,786) | Mean BMI: 25.8
| | Age 50–64 years: 38.0% (n=3,024) | BMI <25: 47% (n=3,741)
| | Age <50 years: 27.0% (n=2,149) | BMI 25–29.9: 33% (n=2,650)
| | Male: 98% (n=7,800) | BMI ≥30: 20% (n=1,592)
| | White race: 75.0% (n=5,969) | [underlined: BMI categories by level of injury]
| | African American: 20.0% (n=1,592) | Paraplegia (n=4,457)
| | Hispanic and other race: 6.0% (n=478) | <25 (normal weight): 45.0%
| | Mean duration of SCI (years): 20 | 25–29.9 (overweight): 33.0%
| | Complete: 37.0% | ≥30 (obese): 23%Tetraiplegia (n=3,502)
| | Incomplete: 28.0% | <25 (normal weight): 50.0%
| | Paraplegia: 56.0% | 25–29.9 (overweight): 35.0%
| | | ≥30 (obese): 17.0%
| | | *P<0.0001, paraplegia vs. tetraplegia
| | | OR for BMI in Veterans. Reference category for BMI is <25 (normal weight)
| | | N=7,959 | Overweight* OR (CI) | | Obese** OR (CI)
| | | Age <50 | 1.0 (reference) | | 1.0 (reference)
| | | Age 50–64 | †1.4 (1.2–1.5) | | †1.4 (1.2–1.5)
| | | Age 65+ | †1.3 (1.2–1.5) | | 1.11 (1.0–1.3)
| | | White | 1.0 (reference) | | 1.0 (reference)
| | | Black | ‡0.8 (0.8–0.9) | | 1.0 (0.9–1.1)
| | | Hispanic | 1.1 (0.9–1.3) | | 1.1 (0.9–1.3)
| | | Tetraplegia | 1.0 (reference) | | 1.0 (reference)
| | | Paraplegia | †1.2 (1.1–1.3) | | †1.5 (1.3–1.7)
| | | *BMI 25–29.9. **BMI ≥30. †P <0.001. ‡P <0.05.
Gupta, 2006^21^ | Retrospective chart review of 408 (387 analyzed) Veterans Affairs patients | Mean age: 55.8 (median 56 years; (range 21–85) | [underlined: Mean BMI]
| USA | Males: 98.3% (n=401) | Paraplegia (n=213): 28.36
| | Females: 1.7% (n=7) | Tetraplegia (n=195): 27.29
| | Mean duration of SCI: 19 (range 2 months-60 years) | [underlined: Prevalence by BMI cut points]
| | Paraplegia: 52.2% (n=213) | BMI <18.5(underweight): 3.6% (n=14)
| | Tetraplegia: 47.7% (n=195) | BMI 18.5–25(normal weight): 27.9% (n=108)
| | | BMI ≥25(overweight): 68.8% (n=255) of which 29.9% were obese (BMI ≥30; n=76)
| | | [underlined: Mean BMI and duration of injury]
| | | 0–5 years: 28.11 (n=60)
| | | 5–10 years: 28.86 (n=46)
| | | 10–15 years: 27.49 (n=39)
| | | 15–20 years: 28.76 (n=49)
| | | 20–25 years: 26.28 (n=52)
| | | >25 years: 27.55 (n=133)
| | | [underlined: Prevalence of those overweight and obese by age]
| | | Age, years
| | | 20–39: BMI ≥25 33.3% (n=11); BMI ≥30 2.8% (n=1)
| | | 40–59: BMI ≥25 65.0% (n=147); BMI ≥30 38.0% (n=86)
| | | 60–74: BMI ≥25 70.1% (n=68); BMI ≥30 17.6% (n=17)
| | | >75: BMI ≥25 61.3% (n=19); BMI ≥30 4.9% (n=2)
Garshick, 2005^5^ | A prospective mortality study of 361 SCI males injured ≥1 year | A. Survivors (n=324) | [underlined: Mean BMI:]
| | Mean age (years): 48.9 | A. Survivors (n=324): 26.3
| | White: 93.2% (n=302) | B. Deceased (n=37): 26.0
| | Nonwhite: 6.8% (n=22)
| | Age at SCI: 32.2
| | Mean duration of SCI (years): 16.7
| | Level of Injury
| | Complete cervical: 21.3% (n=69)
| | T1–T4: 14.8% (n=48)
| | T5–T12: 12.4% (n=40)
| | Others: 10.8% (n=35)
| | Incomplete
| | Cervical ASIA C: 10.8% (n=35)
| | Cervical ASIA D: 12.4% (n=40)
| | Other ASIA C: 7.7% (n=25)
| | Other ASIA D: 9.9% (n=32)
| | B. Deceased (n=37)
| | Mean age (years): 65.0
| | White: 94.6% (n=35)
| | Nonwhite: 5.4% (n=2)
| | Age at SCI: 40.8
| | Mean duration of SCI (years): 24.2
| | Level of Injury
| | Complete cervical: 16.2% (n=6)
| | T1–T4: 10.8% (n=4)
| | T5–T12: 18.9% (n=7)
| | Others: 8.1% (n=3)
| | Incomplete
| | Cervical ASIA C: 16.2% (n=6)
| | Cervical ASIA D: 5.4% (n=2)
| | Other ASIA C: 16.2% (n=6)
| | Other ASIA D: 8.1% (n=3)
Johnston, 2005^22^ | Cross-sectional survey of SCI (n=199) patients in New Jersey (patients from database & community were recruited) compared to national population (n=246,025) | SCI subjects (n=199) | [underlined: Mean BMI]
| USA | Mean age: 39.6 | SCI subjects (n=199): 24.5
| | Male: 74.9% (n=149) | Control (n=246,025): 26.1
| | Female: 25.1% (n=50) | [underlined: BMI Categories]
| | White race: 74.4% (n=148) | A. <18.5 (underweight):
| | African American: 20.1% (n=40) | SCI 7.1%;
| | Asian: 1.5% (n=3) | Control 4.0%
| | Other race: SCI 4.0% (n=8) | B. 18.5–24.9 (normal weight)
| | Mean weight: 168.2 | SCI 48.9%
| | Mean duration of SCI: 8.11 | Control 39.3%
| | Paraplegia incomplete: 27% | C. 25–25.9 (overweight)
| | Paraplegia complete: 71% | SCI 31.3%
| | Paraplegia minimal: 3% | Control 35.2%
| | Tetraplegia incomplete: 53% | ≥30 (obese)
| | Tetraplegia complete: 42% | SCI 12.6%
| | Tetraplegia minimal: 2% | Control 20.9%
| | Control (n=246,025) | [underlined: Use physical activity or exercise to lose weight among overweight/obese]:
| | Mean age: 45.1 | SCI 50.0%
| | Male: 48.3% (n=115,632) | Control 69.8%
| | Female: 53% (n=130,393)
| | White race: 46.2% (n=113,664)
| | African American: 16.4% (n=40,348)
| | Asian: 11.1% (n=27,309)
| | Other race: 26.3% (n=64,705)
| | Mean weight: 171.9
| | Inclusion: >18 years old; traumatic SCI; >1 year post injury
| | Exclusion: normal neurological exam; non-traumatic injury; inability to understand English without translator.
Spungen, 2003^23^ | In a cross-sectional study, 133 male SCI patients were compared to 100 controls matched to age, ethnicity and height | Tetraplegia (n=66) | [underlined: Mean BMI]
| USA | Mean age: 40 | Tetraplegia (n=66): 25.4
| | White race: 31.8% (n=21) | Paraplegia (n=67): 25.8
| | African American: 7.6% (n=5) | Control (n=100): 27.3
| | Hispanic: 60.6% (n=40) | [underlined: Comparisons among groups of total body fat]
| | Mean duration of SCI: 14 | A. Mean total body fat (kg)
| | Motor complete: 68.2% | Tetraplegia: 24.1*
| | Motor Incomplete: 31.8% | Paraplegia: 23.9†
| | Paraplegia (n=67) | Control: 18.7
| | Mean age: 37 (p<0.0005 vs. control) | *p <0.005, tetraplegia vs. control. †p <0.01, paraplegia vs. control
| | White race: 16.4% (n=11) | B. Mean total body fat (kg) by age among groups
| | African American: 9.0% (n=6) | Tetraplegia: <40 (years) 20.3; ≥40 29.2, p<0.01
| | Hispanic: 74.6% (n=50) | Paraplegia: <40 22.7; ≥40 26.2
| | Mean duration of SCI: 12 | Control: <40 18.7; ≥40 18.8
| | Motor complete: 73.1% | C. Mean percent of body fat by age among groups
| | Motor Incomplete: 26.9% | Tetraplegia: <40 31%; ≥40 39%, p<0.01
| | Complete (n=94) | Paraplegia: <40 30%; ≥40 36%, p<0.01
| | Incomplete (n=39) | Control: <40 21%; ≥40 23%
| | Control (n=100) | D. Mean total body fat (kg), motor-complete and incomplete: mean total body fat (kg)
| | Mean age: 44 | Tetraplegia: Complete 23.3; Incomplete 26.1
| | White race: 19% (n=19) | Paraplegia: Complete 24.7; Incomplete 21.7
| | African American: 6% (n=6) | E. Mean percent of body fat, motor-complete and incomplete:
| | Hispanic: 75% (n=75) | Tetraplegia: Complete 34%; Incomplete 35%
| | | Paraplegia: Complete 33%; Incomplete 28%
Bauman, 1999^15^ | Cohort of outpatient SCI patients (n=320) seen for annual exam vs. able-bodied controls (n=303) matched by age and ethnicity | SCI subjects (n=320) | [underlined: Mean BMI and Body Fat]
| USA | Mean age: 41 (20–77) | A. SCI subjects (n=320)
| | Male: 73.0% (n=234) | Mean BMI: 25 (13.8–54.8)
| | Female: 27.0% (n=86) | Estimated body fat: 36.0% (21.1–72.3)
| | White: 47.0% (n=150) | BMI ≥27.8: 28.0%
| | African American: 28.0% (n=90) | B. Sedentary able-bodied controls (n=303)
| | Hispanic: 26.0% (n=83) | Mean BMI: 29.9 (19.7–49.9) (p<0.0001 vs. SCI)
| | Mean duration of SCI: 15 (1–57) | Estimated body fat: 31.0% (10.2–72.5) (p<0.0001 vs. SCI)
| | Motor complete: 65.6% | BMI ≥27.8: 64.0% (p<0.0001 vs. SCI)
| | Motor incomplete: 34.4%
| | Sedentary able-bodied controls (n=303)
| | Mean age: 42 (21–75)
| | Male: 81.0% (n=245)
| | Female: 16.0% (n=48)
| | White: 56.0% (n=170)
| | African American: 29.0% (n=88)
| | Hispanic: 16.0% (n=48)
Bauman, 1999^2^ | Cross-sectional study including a convenience sample of 201 SCI patients from a single clinical center who had oral glucose tolerance tests. Patients were subgrouped by level of injury. | Mean age (years): 39 | [underlined: Mean BMI (kg/m^2^):]
| USA | Male: 84% (n=169) | Overall: 25
| | Female: 16% (n=32) | Tetra complete: 23
| | White: 27% (n=54) | Tetra incomplete: 26
| | Latino: 57% (n=114) | Para complete: 25
| | African American: 14% (n=28) | Para incomplete: 25
| | BMI: 25 | Total body fat (%):
| | Injury: | Overall: 34
| | Mean duration of SCI (years): 13 | Tetra complete: 34
| | Mean age at injury: 25 | Tetra incomplete: 35
| | Tetra complete: 28% (n=56) | Para complete: 34
| | Tetra incomplete: 12% (n=25) | Para incomplete: 31
| | Para complete: 42% (n=84)
| | Para incomplete: 18% (n=36)
Anson, 1996^24^ | Data from 348 post-acute SCI patients were collected during routine followup in Georgia | Mean age: 36.6 (median 33 years; range 32.4–44.2) | [underlined: Weight status]
| USA | Male: 81.9% (n=285) | Underweight 22.3% (n=69); Ideal weight 37.9% (n=117)
| | Female: 18.1% (n=63) | Overweight 26.9% (n=83); Obese 12.9% (n=40)
| | White 80.2% (n=279) | [underlined: Weight status by years since injury]
| | Non-white 19.5% (n=69) | Time since injury
| | [underlined: Time since injury] | A. 1–2 years
| | 1–2 years 25.9% (n=90) | Underweight 21.6% (n=19); Ideal weight 39.8% (n=35)
| | 3.5 years 25.3% (n=88) | Overweight 29.5% (n=26); Obese 9.1% (n=8)
| | 6–10 years 29.3% (n=102) | B. 3–5 years
| | 11–15 years 11.8% (n=41) | Underweight 20.3% (n=16); Ideal weight 41.8% (n=33)
| | >15 years 7.8% (n=27) | Overweight 24.1% (n=19; Obese 13.9% (n=11)
| | | C. 6–10 years
| | | Underweight 25.6% (n=21); Ideal weight 37.8% (n=31)
| | | Overweight 24.4% (n=20); Obese 12.2% (n=10)
| | | D. 11–15 years
| | | Underweight 27.0% (n=10); Ideal weight 24.3% (n=9)
| | | Overweight 27.0% (n=10); Obese 21.6% (n=8)
| | | E. >15 years
| | | Underweight 13.0% (n=3); Ideal weight 39.1% (n=9)
| | | Overweight 34.8% (n=8); Obese 13.0% (n=3)
| | | *Weight categories not defined
Zhong, 1995^10^ | SCI men studied during annual physical exam. | 197 men with chronic SCI, 103 paraplegia and 94 tetraplegia | [underlined: Mean BMI]
| Veterans Affairs patients, USA | Mean age: 50 (21–77) | 25 (15.8–47.8)
| | Mean duration of SCI: 18 (1–49) | BMI >27.8 (n=48)
| | Exclusion criteria: No prior history of diabetes or gout | There was a positive correlation between BMI and % body fat (r=0.59, p<0.001)
| | | By linear regression analysis, there was a positive correlation between BMI (r=0.20, p<0.01) and LDL (r=0.17, p<0.05), but not with age, date of injury, peak plasma glucose, or any other lipoprotein value.
Bauman, 1992^18^ | Veteran SCI patients, matched for age and BMI, were compared to veteran controls | Paraplegia: n=50 | [underlined: Mean BMI]
| USA | Mean age (years): 49.5 | Paraplegia: n=50: 26.0
| | Mean duration of SCI: 17.6 | Tetraplegia: n=50: 24.0
| | Tetraplegia: n=50 | Control: n=50: 26.8
| | Mean age: 46.2
| | Mean duration of SCI: 15.0
| | Control: n=50
| | Mean age: 48.8

Table 2 Cardiovascular events in adults with chronic traumatic SCI

Study | Sample | | Risk factors | Outcomes
Cardus, 1992^25^ | 640 patients over 18 year of age, more than 9 months after traumatic SCI who resided in the county area and had to use assistive device for walking. | | Risk factors of cardiovascular disease; age, blood pressure, blood cholesterol, fasting glucose, ECG abnormalities, self reported smoking. | Risk of cardiovascular diseases using Framingham risk calculation with cut off for low risk as 3% - probability of healthy 50 year old men, non smoker, non diabetic, with normal ECG, systolic blood pressure blow 125 mmHg, and blood cholesterol less than 200 mg.
Case-control study to compare probability of cardiovascular diseases in patients with SCI compared to the able-bodied persons. | 96 eligible. Controls: 96 non trained able bodied men matched by age. | | Age at injury and the time after injury. | Age | Time After Injury (Months) | | Number | | | % with Risk >3% in SCI vs. Controls
Adjustment not reported. Matching by age. | | | | 21±3.2 | 65±27 | | 25 | | | 0 vs.1
| | | | 19.1±3.5 | 252±96 | | 30 | | | 3.1 vs. 8.3
| | | | 44.7±12 | 57±21 | | 29 | | | 13.5 vs.14.5
| | | | 37.4±6.6 | 232±122 | | 12 | | | 9.4 vs. 7.2
Krum, 1992^19^ | 327 patients with SCI and age and sex matched controls from the 1983 Australian Risk Factor Prevalence Study. | | Cardiovascular risk factor score (RFS) derived from the MRFIT study (age, diastolic blood pressure (DBP), total cholesterol (TC) level, cigarettes/day, sex): =0.1091*Age+0.288*DBP+0.008*Total cholesterol+0.227*cigarettes/day. | Prevalence of arterial hypertension, angina, myocardial infarction, cerebrovascular accident, and diabetes. Age adjusted percentile position of scores were compared to the general population.
Cross sectional analysis of cardiovascular morbidity in association with risk factor scores among Australian adults with spinal cord injury. | Exclusion criteria not reported but only 102 patients who completed questionnaire were analyzed. | | | Prevalence | | | SCI | | | General Population
Time: 1983 | Population: 102 patients, 19% female, 25–64 years old; 34% more than 10 years after injury; 40% with cervical, 35% with lower thoracic, 13% with upper thoracic, and 12% with lumbar levels of injury; ~41% with Frankel Grade A of completeness complete motor and sensory deficit | | | Hypertension | | | 9 | | | 20
Adjustment: age | | | | Angina | | | 2 | | | 2.5
Matching by gender and age | | | | MI | | | 1.9 | | | 1.8
| | | | Cerebrovascular accident | | | 1 | | | 0.7
| | | | Diabetes | | | 6 | | | 2
| | | | | | | Odds Ratio (95% CI)
| | | | Hypertension | | | 0.4 | | 0.17 | | 0.92
| | | | Angina | | | 0.67 | | 0.11 | | 4.08
| | | | MI | | | 1 | | 0.14 | | 7.24
| | | | Cerebrovascular diseases | | | 1 | | 0.06 | | 16.21
| | | | Diabetes | | | 3.13 | | 0.62 | | 15.89
| | | | Cardiac risk factor score
| | | | Age | | | Mean of Percentile Position in Comparison to Age Matched Subjects in the National Heart Foundation Study | | | STD
| | | | 25–29 | | | 11 | | | 15
| | | | 30–34 | | | 18 | | | 18
| | | | 35–39 | | | 30 | | | 15.5
| | | | 40–44 | | | 21 | | | 21
| | | | 45–49 | | | 45 | | | 28
| | | | 50–54 | | | 34 | | | 37.5
| | | | 55–59 | | | 26 | | | 17
| | | | 60–69 | | | 44 | | | 17.5
| | | | all ages | | | 27.5 | | | 16.5
| | | | >10 years after injury | | | 34 | | | 29
Whiteneck, 1992^26^ | 834 individuals with 20 or more years after SCI treated at the British spinal injury centers | | Level and completeness of injury and age at injury. | Disease-specific mortality. Cardiovascular deaths 84 (23.2%), 38 patients died from acute myocardial infarction, 31 from other disease of heart, 10 from cerebrovascular diseases, 5 from other circulatory problems.
Retrospective analysis to examine morbidity and mortality in SCI patients compared to the general population. | Exclusion criteria: childhood injuries, injuries in older adults (>55 years), not willing to complete interview. | | Paraplegia with Frankel grades A, B, or C - no functional motor preservation; | CVD Mortality | | | N | | | % among Total Deaths
Time: 1943-1970 | Population: 13% female, 412 survivors, 282 (68%) completed the interview, Age at time of injury was between 15 and 55 years—15–24 years 42%, 25–34 years 27%, 35–44 years 18%, 45–55 years 13%; median survival time 32 years; 85% survived at 10 years, 71% at 20 years, 53% at 30 years, and 35% at 40 years after injury. | | Quadriplegia with Frankel grades A, B, or C - no functional motor preservation; | All cases | | | 84 | | | 23.2
Adjustment age, gender, level of injury, time after injury | | | Para- or quadriplegia with Frankel grades D or E - functional motor preservation | Para ABC | | | 48 | | | 23.2
| | | | Quadriplegia ABC | | | 8 | | | 14.1
| | | | All D and E | | | 28 | | | 28.3
| | | | Annual CVD mortality rates/1,000 SCI cases and age matched
| | | | Age | | | SCI | | | General Population
| | | | 15–24 | | | 0.8 | | | 0.1
| | | | 25–34 | | | 0.7 | | | 0.2
| | | | 35–44 | | | 2.4 | | | 0.8
| | | | 45–54 | | | 4.4 | | | 3.2
| | | | 55–64 | | | 13 | | | 9.4
| | | | 65–74 | | | 21 | | | 25.1
| | | | 75–84 | | | 102 | | | 61.4
| | | | CVD Incidence by age (episodes/100 cases per year)
| | | | Age at Episode | | | | | Heart-Circulatory
| | | | <30 | | | | | 2
| | | | 30–39 | | | | | 2.9
| | | | 40–49 | | | | | 5.2
| | | | 50–59 | | | | | 8.1
| | | | 60+ | | | | | 19
| | | | Years After Injury
| | | | <10 | | | | | 2.9
| | | | 10–19y | | | | | 5.4
| | | | 20–29y | | | | | 10
| | | | 30+ | | | | | 14
DeVivo, 1993^27^ | 9,135 persons injured between 1973 and 1984 and treated at any of 13 regional spinal cord injury care systems | | Age, neurological level, and extent of spinal cord lesion | Standardized mortality ratios versus general population (ratio of 1 = no increase in cause-specific death rate) (SMR)
Retrospective analysis to compare age, sex, race, and cause-specific mortality rates in patients with SCI 12 years after injury vs. the general population. | Exclusion criteria: not reported. | | | Ischemic heart disease (ICD codes 410–414)
Time: 1973–December 21, 1985 | Population: 854 SCI patients who died during followup time. | | | Non ischemic heart disease (ICD codes 420–429)
Adjustment: standardization by age, sex, and race | | | | Cerebrovascular diseases (ICD codes 430–438)
| | | | Diseases of arteries (ICD codes 440–448)
| | | | Mortality in SCI patients:
| | | | Cause | | | Actual Death | | SMR | | SMR 95% CI
| | | | Ischemic heart disease (ICD codes 410–414) | | | 61 | | 1.3 | | 1–1.6
| | | | Non ischemic heart disease (ICD codes 420–429) | | | 84 | | 5.6 | | 4.4–6.8
| | | | Cerebrovascular diseases (ICD codes 430–438) | | | 22 | | 1.8 | | 1–2.6
| | | | Diseases of arteries (ICD codes 440–448) | | | 14 | | 4.5 | | 2.1–6.9
Imai, 1994^8^ | 307 (244 responded) men with SCI identified during the National Livelihood Basic Survey in Japan engaged in light work at special centers, who had medical examination for blood pressure and medical history. | | Level of injury: C-T5; T6–T10; T11-L2; L2; Age: 40^th^, 50^th^, 60^th^ | Outpatient rate of hypertension, renal diseases, and diabetes = (number of outpatients/population studied) * 1,000
Cross-sectional analysis of morbidity rates and standardized morbidity ratios according to the site of injury compared to the general population. | Exclusion criteria: 195 were analyzed among 228 eligible for not reported reasons. | | | Standardized morbidity ratios=(total number of outpatients/ expected number of outpatients) * 100
Time: 1990 | Population: mean age was 49.5 years old; the average post-injury period 17.9 years; 19 patients injured at level C-T5, 24 at T6–T10, 139 at T11-L1, and 13 at L2 or lower. | | | Obesity. Self reported treatment with anti-hypertensive medications.
Adjustment: age | | | | Level of Injury | | | N | | Prevalence/ 1,000 | | Standardized Morbidity Ratios
| | | | | | | | | | | General Population = 100
| | | | C-T5
| | | | Renal diseases | | | 2 | | 105 | | 2,049
| | | | T6–T10
| | | | Renal diseases | | | 6 | | 250 | | 4,187
| | | | Hypertension | | | 5 | | 208 | | 300
| | | | T11-L2
| | | | Hypertension | | | 21 | | 151 | | 221
| | | | Renal diseases | | | 18 | | 129 | | 2,194
| | | | Diabetes mellitus | | | 9 | | 65 | | 326
| | | | Hypotension | | | 3 | | 22 | | 607
| | | | L2
| | | | Hypertension | | | 5 | | 385 | | 697
| | | | Renal diseases | | | 4 | | 308 | | 5,569
| | | | Diabetes mellitus | | | 2 | | 154 | | 945
| | | | Prevalence of obesity:
| | | | Age | Obesity
| | | | 40^th^ | 6.8
| | | | 50^th^ | 2.5
| | | | 60^th^ | 1
| | | | Treatment with Antihypertensive Medications
| | | | Age | | | SCI | | | General Population
| | | | 30^th^ | | | 9.1 | | | 2
| | | | 40^th^ | | | 15.6 | | | 5.1
| | | | 50^th^ | | | 21.8 | | | 14.4
| | | | 60^th^ | | | 45.5 | | | 22.8
Nam, 1994^28^ | 1,027 patients admitted to medical centers with stroke and 2,007 patients with SCI (paraplegia or quadriplegia) including 13 patients with stroke. | | Traumatic SCI | Prevalence of stroke after traumatic SCI: 0.10 percent (2 cases/2,007 SCI patients.
Retrospective medical chart review to test the hypothesis that the SCI population has an increased incidence of stroke, and to identify stroke risk factors unique to SCI patients. | Exclusion criteria: non traumatic SCI, stroke before SCI. Population: 2 patients with traumatic SCI followed by stroke.
Time: 1980-1990. | Population: average age 37.2±16.1years
Adjustment not reported
Levi,1995^29^ | 326 patients with SCI from the Stockholm Spinal Cord Injury Study, residents of the Greater Stockholm area. | | Spinal cord injury | Prevalence of diabetes, hypertension, obesity, cardiac problems and self reported use of cardiac medications.
Cross-sectional Stockholm Spinal Cord Injury Study. | Control participants in the Swedish Annual Level of Living Survey (1,978 interviews) | | | Disorder | | SCI | SCI/Controls
Time: 1988-89. | Exclusion criteria: residents of Gotland | | | | | % | Crude Odds Ratio | | p Value | Adjusted Odds Ratio | p Value
Adjustment: age, sex, socioeconomic status | Population: 80% males | | | Diabetes mellitus | | 1 | 1.01 | | 0.98 | 1.2 | 0.74
| | | | Circulatory | | 2 | 0.22 | | 0.0003 | 0.25 | 0.01
| | | | Hypertension | | 0
| | | | Cardiac | | 2 | 0.64 | | 0.35 | 0.72 | 0.5
| | | | Use of cardiac medication | | 2 | 0.46 | | 0.07 | 0.69 | 0.4
Levi, 1995^30^ | 353 subjects with traumatic SCI, participants in The Stockholm Spinal Cord Injury Study. | | ASIA/IMSOP Impairment Scale Grade level of injury as cervical complete, thoracic incomplete, lumbo-sacral complete, lumbo-sacral incomplete; age at injury as continuous variable; duration of injury as shorter (0–4 years), intermediate (5–17 years), longer (18–44 years) | Prevalence of cardiovascular symptoms: ankle-leg edema, chest pain, palpitations.
Cross-sectional analysis of the associations between patient characteristics and prevalence of internal diseases and symptoms. | Exclusion criteria- not reported. | | | Risk Factors | | | N | | | % with CVD Symptoms
Adjustment: age, gender, duration of injury, functional status | Population: 19% female | | | Total | | | 353 | | | 58
| 0–4 years after injury | 23.97% | | Males | | | 286 | | | 55
| 5–17 years after injury | 48.76% | | Females | | | 67 | | | 69
| 18–44 years after injury | 24.52% | | Age at injury 21–40 | | | 162 | | | 57
| | | | Age at injury 41–77 | | | 89 | | | 61
| | | | Duration of injury 0–4 years | | | 87 | | | 48
| | | | Duration of injury 5–17 years | | | 177 | | | 55
| | | | Duration of injury 18–44 years | | | 89 | | | 72
| | | | Cervical injury, complete | | | 53 | | | 72
| | | | Cervical injury, incomplete | | | 93 | | | 57
| | | | Thoracic injury, complete | | | 78 | | | 72
| | | | Thoracic injury, incomplete | | | 48 | | | 58
| | | | Lumbosacral injury, complete | | | 8 | | | 62
| | | | Lumbosacral injury, incomplete | | | 47 | | | 38
McGlinchey-Berroth, 1995^9^ | 534 patients with SCI admitted to the high quality Spinal Cord Injury Service of the VA medical center (part of the Aging with a Long-Term Disability Research Program database). | | Group 1 (N=225) persons <50 years of age at the time of injury and <5 years at index submission. | Hospitalization due to myocardial infarction (ICD-9-CM 401.9), diabetes (ICD 250.00 to 250.9), and hypertension (ICD 401.0 to 401.9).
Cross-sectional analysis of hospitalizations among patients surviving late life injury. | Exclusion criteria: not available discharge summary; current hospitalization, transfer to the long term care facility. | | Group 2 (N=162) <50 years of age at the time of injury but >50 years at the time of index admission. | Prevalence of CVD in SCI group
Time: 1989-1992. | Population: 510 discharged from hospitals were included in the analysis; mean age of 50 years (16–84 years); 23% were at least 65 years of age; 16±13.1 years after injury, 12±12 hospital admissions since injury; 99% male. | | Group 3 (N=93) persons >50 years of age at the time of injury. | Outcomes | | Group 1 | | Group 2 | | Group 3 | | Total
Adjustment not reported. | | | | N | | 255 | | 162 | | 93
| | | | Myocardial infarction | | 5.09 | | 25.3 | | 33.33
| | | | Diabetes | | 3.92 | | 12.34 | | 22.58 | | 9.8
| | | | Hypertension | | 5.09 | | 25.3 | | 33.33 | | 16.67
| | | | Stroke | | 0 | | 0 | | 0
Imai, 1996^7^ | 244 males with SCI at several Rehabilitation Centers (Workman's Accident Compensation Rehabilitation Workshops). | | Level of injury: C-T5; T6–T10; T11-L2; L2- | Outpatient rate = (number of outpatients/population studied) * 1,000
Cross-sectional analysis of morbidity in SCI patients compared to the general Japanese population. | Exclusion criteria: 20% did not respond to the questionnaire. | | Age: 40^th^, 50^th^, 60^th^ | Standardized morbidity ratios (SMR) = (total number of outpatients/expected number of outpatients) * 100
Time: 1989. | Population: Age 22 to 69 years (mean 47.6); mean postinjury periods 17.3 years; C-T5 level -1%; T6–T10 12%; T11-Ll 69%; L2 -8%. | | | | SCI Male | | General Pop, Male | | N Outpatients with SCI/244 | | SMR
Adjustment not reported, standardization by age with general population | Control group (general population). National Livelihood Basic Survey conducted by the Ministry of Health and Welfare in 1989, on 800,000 people in 240,000 households. | | | All CVD | 536.9 | | 224.8 | | 127 | | 337
| | | | Hypertension | 163.9 | | 45.4 | | 40 | | 250
| | | | Hypotension | 16.4 | | 2.5 | | 4 | | 472
| | | | Ischemic heart diseases | 16.4 | | 9 | | 4 | | 146
| | | | Other diseases of circulatory system | 8.2 | | 7 | | 2 | | 93
| | | | Diabetes mellitus | 61.5 | | 12.2 | | 15 | | 323
Hartkopp,1997^31^ | 888 individuals (713 men and 175 women) who survived SCI and were rehabilitated at the Centre for Spinal Cord Injured in Hornbnk, Denmark. | | Neurological level of last preserved segment at time of injury, functional level according to Frankel scale at last followup: functionally complete tetraplegia (cervical cord lesions and Frankel class A-C), functionally complete paraplegia (thoracic and lumbar cord lesions and Frankel class A-C), Frankel class D, and Frankel class E. | Mortality from cardiovascular diseases from The National Registry of Causes of Death and the general public records of vital statistics Denmark Statistic; medical records, death certificates, and post mortem records.
Retrospective cohort to examine mortality among SCI compared to the general population. | Exclusion criteria: permanent respiratory support, severe SCI with specialized treatment | | Years of injury: 1953-1971 and 1972-1990 | | | | Men | | Women | | All
Time: SCIs that occurred between January 1, 1953, and December 31, 1990; deaths before December 31, 1992. | Population: median age at the time of injury 27.5 in 1953-1971 and 28.5 from 1972-1990 | | | Death (ICD codes) | | | N | % | N | % | N | %
Adjustment standardization by age | | | | Cardiovascular disease (390–458) | | | 47 | 24 | 9 | 23 | 56 | 24
| | | | Ischemic heart disease (410–414) | | | 19 | 10 | 3 | 8 | 22 | 9
| | | | Cerebrovascular disease (430–438) | | | 6 | 3 | 2 | 5 | 8 | 3
| | | | Lung embolus (450) | | | 6 | 3 | 0 | 0 | 6 | 3
| | | | Total | | | | | | | 236 | 100
| | | | | Tetraplegia C | | Paraplegia, T-L
| | | | Frankel | A-C | | A-C | | D | | E
| | | | | N | % | N | % | N | % | N | %
| | | | Cardiovascular disease | 9 | 13 | 14 | 20 | 27 | 36 | 6 | 24
| | | | Ischemic heart disease | 2 | 3 | 5 | 7 | 10 | 14 | 5 | 20
| | | | Cerebrovascular disease | 2 | 3 | 2 | 3 | 4 | 5
| | | | Lung embolus | 1 | 1 | 1 | 1 | 3 | 4 | 1 | 4
| | | | Total | 67 | | 69 | | 75 | | 25
| | | | Standardized mortality ratios (SMR) = observed to expected number of deaths
Rish, 1997^13^ | 230 patients with SCI identified in the Vietnam Head and Spinal Cord Injury Study Registry who survived more than 72 hours, with significant myelopathy; and with available medical records. | | Level of injury; Myelopathy (quadriplegic, paraplegic, complete, incomplete); Mechanism of injury (penetrating wounds, closed injuries) | The initial diagnosis of hypertension, obesity, diabetes, coronary artery disease, myocardial infarction, cerebral vascular accidents. Death from myocardial infarction.
Retrospective review of the charts to analyze incidence and causes of deaths among Vietnam veterans over 25 periods after SCI. | Exclusion criteria not reported. | | | Prevalence of diabetes and CVD n SCI patients:
Time: 1967-1970 to 1995. | Population: mean age at injury 21.4 years, with previous excellent health (active duty military personnel); median time after injury 25 years | | | Diagnosis | | | N | | | %
Adjustment not reported. | | | | Hypertension | | | 48 | | | 21
| | | | Obesity | | | 32 | | | 14
| | | | Diabetes | | | 29 | | | 13
| | | | Coronary artery disease | | | 14 | | | 6
| | | | Myocardial infarction | | | 8 | | | 3
| | | | Cerebrovascular accidents | | | 4 | | | 2
| | | | Mortality from Myocardial infarction 2.2% (5 cases/230 patients)
| | | | Year After Injury | | | | Death from Myocardial Infarction
| | | | 5 | | | | 1
| | | | 20 | | | | 2
| | | | >20 | | | | 2
DeVivo, 1999^32^ | 28,239 consecutive patients admitted to the model system or to a Shriner's Hospital within 1 year of traumatic SCI who survived at least 24 hours after injury. | | Age at injury, neurological level of injury (C1–C4, C5–C8, T1-S5), Frankel grade or ASIA Impairment Scale (each grade separately), injury year (1973-1977, 1978-1982, 1983-1987, 1988-1992, 1993-1998). | Length of survival confirmed with the Social Security Death Index and cause of death from the National Spinal Cord Injury Statistical Center, hospital discharge summaries, death certificates, and autopsy reports.
Retrospective cohort to examine trends in mortality and causes of death among patients with SCI. | Exclusion criteria not reported. Population: 19% females; 67.6% Caucasian, 20.7% African American, 8.1% Hispanic, 3.6% Asian, Native American, or other; 54% of injuries occurred between the ages of 16 and 30 years, and 23% between 31 and 45 years; 53% cervical, C5–C8 34.5% and C1–C4 18.5% of the population; 53.8% neurologically complete, 27.2% motor functional, 19% sensory sparing or motor nonfunctional; 2.9% were ventilator-dependent. | | | Standardized mortality ratio - ratio of actual to expected deaths for each neurological category and ventilator status from each of three starting points (time of injury, first anniversary of injury, and fifth anniversary of injury) until followup termination. These standardized mortality ratios were then applied to 1994 general population mortality rates (the most recent available) to determine life expectancies.
Time: 1973-1998 | | | | CVD mortality after 1 year of injury:
Adjustment: age at injury, sex, race, etiology of injury, number of days from injury, neurological level of injury, Frankel grade or, American Spinal Injury Association (ASIA) Impairment Scale, ventilator dependency, sponsor of care, autopsy. | | | | Year of Death | N of Deaths | | Heart, % | | Stroke, % | | Arteries, %
| | | | 1973-77 | 74 | | 10.8 | | 1.4 | | 0.0
| | | | 1978-82 | 278 | | 15.8 | | 4 | | 1.1
| | | | 1983-87 | 370 | | 20.3 | | 3.5 | | 2.2
| | | | 1988-92 | 340 | | 18.5 | | 3.8 | | 1.8
| | | | 1993-98 | 481 | | 20.6 | | 2.9 | | 1.2
| | | | Total | 1,543 | | 18.8 | | 3.4 | | 1.5
| | | | Adjusted Odds Ratios for CVD Death Occurring After the First Post-injury Year Relative to All Other Causes:
| | | | | Heart, Stroke, and Arteries
| | | | 1978-82 | 1.62 (0.74–3.55)
| | | | 1983-87 | 1.86 (0.86–4.05)
| | | | 1988-92 | 1.35 (0.61–2.99)
| | | | 1993-1998 | 1.37 (0.61–3.07)
Groah, 2001^33^ | 834 patients alive >20 years after spinal cord injury identified in 2 British Spinal Injuries Centers | | Level of injury and Frankel/ASIA grade: | Incidence of cardiovascular diseases calculated by dividing the number of new CVD events by the total SCI person-time for each neurological category. Cardiovascular disease outcomes defined by ICD/9 codes 390–448 and 745–747 and obtained through medical record review: All CVD, coronary heart disease, hypertension, cerebrovascular disease, valvular disease, and dysrhythmia, “other cardiovascular disease” cardiomegaly, congestive heart failure, thrombophlebitis, endocarditis, deep venous thrombosis, and venous insufficiency.
Prospective observation to examine incidence of cardiovascular disease in people with long-term SCI. | Eligible 545, 15–55 years old at the time of injury, initially admitted to one of the 2 British SCI centers within 1 year of injury, residence in a 13-county catchment area at the time of injury. | | 1. Tetraplegia Frankel/ ASIA Impairment grade A, B, or C (Tetra ABC)
Time: 1970-1993 | Exclusion criteria: death during 20 years after injury, congenital cardiovascular diseases, subclinical disease. | | 2. Paraplegia Frankel/ ASIA Impairment grade A, B, or C (Para ABC)
Followup after injury: 20 years | Population: mean age 57±10 years, duration of SCI 29±6 years, females 14% | | 3. All Frankel/ASIA Impairment grade Ds (All D) (37% between C4 and C7 and 40% between T11 and L4)
Adjustment: age
Davies, 2002^34^ | 140 patients with segmental, nonprogressive traumatic SCI, benign tumors, transverse myelitis, vascular infarcts, and congenital defects. | | Self reported current lifestyle risks using selected sections of Lyndhurst Computerized Health Risk Assessment (LCHRA): Physical activity, BMI, cigarette use and alcohol consumption. Variation in lifestyle since SCI. Internal consistency reliabilities for the subscales used in this study ranged from a low a = 0.56 for bladder management to a high a = 0.82 for physical activity. | Cardiovascular morbidity measured using the London School of Hygiene Questionnaire on Chest Pain and Intermittent Claudication (LSHQCPIC) validated against physician diagnosis in general and patient populations with specificity 48–98% and sensitivity from 25–83%. In univariate analyses (correlations and chi-squares), cardiovascular morbidity was associated at the p <0.25 level with duration of cigarette use, age, monthly alcohol consumption, bladder self-care, frequency of excessive alcohol use, BMI, and a complete lesion.
Cross-sectional analysis to assess the risk of cardiovascular morbidity in adults with SCI relative to lifestyle risk factors. | Exclusion criteria: death (20), refusal to participate (10), poor health (1) | | | | | | | | | OR | 95% CI
Time: 1972-1992 | Loss of followup: 12.3% | | | Age | | | | | | 1.04 | 0.99 | 1.08
Adjustment: age, duration of cigarette use | Population: 97 patients, mean age 47.5±4.5; 10% female; age at injury 31.67±16.4; duration of disability 15.9±10.1 years. | | | Duration of cigarette use | | | | | | 1.03 | 0.99 | 1.07
| Quadriplegia | 42% | | | | | | | | N | Prevalence
| Paraplegic | 57% | | Cardiovascular morbidity | | | | | | 13 | 13.4
| Undetermined | 1%
| Complete | 33%
| Incomplete | 64%
| Undetermined | 3%
| Traumatic | 87%
| Nontraumatic | 13%
Prakash, 2002^6^ | 47,070 patients with at least one ECG obtained in the Palo Alto Veterans Affairs Health Care System | | Level of injury by the effect on sympathetic innervation of heart: intact injury Level T6 and below or impaired injury level T5 and above. Age below and above 65 years | Clinical events: Diabetes, hypertension, coronary heart disease, congestive heart failure, pulmonary disease. Standardized computerized ECG. Left ventricular hypertrophy: R wave >11mm in lead aVL, an S wave of >24mm in lead V1, an R wave of >26mm in lead V5, or SV1 + RV5 or V6 >35mm. Abnormal ECG as the presence of one of: right or left bundle branch blocks, intraventricular conduction delay, right ventricular hypertrophy or LVH, abnormal ST depression, atrial fibrillation, or QTc greater than 450 msec. Abnormal ST depression: ST depression >0.5mm in any one of leads II, V2, or V5. LVH with strain as LVH voltage criteria with abnormal ST depression. Mortality obtained from the Social Security Death Index.
Retrospective cohort to examine prevalence of ECG abnormalities in individuals with spinal cord injuries. | Exclusion criteria: inpatient setting or emergency room at the time of ECG
Time: 1987-1999 | Population: 26,734 able-bodied male veterans and 654 patients with SCI (age 50 ± 14)
Followup: 5.6 years
Adjustment not reported
Cardenas, 2004^35^ | Patients with traumatic SCI identified in the Model System (hospitalized between acute hospitalization and comprehensive inpatient rehabilitation, admitted to a Model System within 365 days of injury) who reside in the geographic region in which the Model System facility is located. 5,180 patients analyzed, 4,251 (82.1%) had year-1 followup interviews; 3,904 (91.8%) were matched by the Model System data. Exclusion criteria: no followup interviews with system identification code and unique patient identifier in the Model Systems Form II at first year anniversary; refusal to participate (1 site); small sample size of patients at sites. | | Residence at discharge; payer, length of stay at time of initial rehabilitation; level of injury and functional status at discharge from initial rehabilitation. | A rehospitalization is any overnight hospitalization, even a 1-night hospitalization for observation, but does not include an emergency department visit obtained by subject interview and not by documentation of hospital. No cardiovascular disease specific multivariate risk for rehospitalization reported. Hospitalization for CVD:
Cross-sectional analysis at several time points to examine the reasons for rehospitalization in persons with acute traumatic spinal cord injury. | Loss of followup: 17.9 %. | | | Year of Followup | | | Total | | | % of CVD
Time: 1995-2002; 20 years of followup. | Population: 3,904 patients with 11,047 followup interviews, 21.4% female, 61.4% White; | | | 1 | | | 930 | | | 5
Adjustment: age, gender, education, ethnicity, marital and vocational status. | C1–4 ASIA grades A, B, C: 4.6% | | | 5 | | | 411 | | | 4
| C1–4 ASIA grade D: 6.1% | | | 10 | | | 364 | | | 4
| C5–8 ASIA grades A, B, C: 19.1% | | | 15 | | | 323 | | | 4
| C5–8 ASIA grade D: 8.5% | | | 20 | | | 294 | | | 3
| T1-S5 ASIA grades A, B, C: 33.1% | | | Total | | | 2,249 | | | 4
| T1-S5 ASIA grade D: 4.2%
Garshick, 2005^5^ | 402 subjects with chronic SCI, >20 years of age previously treated by the SCI Service at Veterans Affairs Boston Healthcare System, registered in the National Spinal Cord Injury Association database in Massachusetts, New Hampshire, Vermont, Maine, and Rhode Island | | Hypertension and diabetes diagnosed by a doctor, heart disease as treatment for ‘heart trouble’ reported in the 10 years prior to study entry using the respiratory health questionnaire based on the ATS DLD-78 adult respiratory questionnaire. Medical records were reviewed for subjects who reported diabetes, hypertension, or heart disease for doctor-confirmed diagnosis in a discharge summary, problem list, or in a progress note. | Date of death and cause-specific mortality through December 2000 using the National Death Index. Standardized mortality ratios (SMR) using the Life Table Analysis System (LTAS) provided by the National Institute of Safety and Health.
Prospective cohort study to examine the association between comorbid medical conditions and other health related factors and mortality in patients with chronic SCI. | Exclusion criteria: other neurological diseases (polio, stroke, or multiple sclerosis), mechanical ventilation or tracheotomy. | | | Causes of death using ICD codes: Diabetes (250); Diseases of the heart (390–398, 402, 404, 410–414, 420–429); Other diseases of the circulatory system (401, 403, 405, 415–417, 430–438, 440–459); Diseases of the arteries, veins, and pulmonary circulation (415–417,440–459).
Time: 1994-2000 | Population: 361 males (289 veterans and 72 nonveterans), mean age: 50.6 ± 15.0 years (range 23–87), mean years since injury 17.5 ± 12.8 years (range 1.0–56.5); 93% Caucasian, 5% African American, and 2% other races, 92%, SCI was due to traumatic injury. 37 deaths. | | | | Alive | | | | Died
| | | | Heart Disease | 19 | | 5.90% | | 12 | | 32.40%
| | | | Hypertension | 79 | | 24.40% | | 18 | | 48.70%
| | | | Diabetes | 27 | | 8.30% | | 9 | | 24.30%
| | | | | | | Underlying Cause of Death | | Contributing Cause of Death | | Total
| | | | Circulatory system disorder | | | 21.60% | | 18.90% | | 40.50%
| | | | 390–59 | | | 8 in 37 | | 7 in 37 | | 15 in 37
| | | | | | | | | SMR (95% CI)
| | | | Diabetes | | | | | 3.74 | | 0.45–13.51
| | | | Diseases of the heart | | | | | 0.59 | | 0.19–1.38
| | | | Other diseases of the circulatory system | | | | | 1.49 | | 0.31–4.36
| | | | Diseases of the arteries, veins, and pulmonary circulation | | | | | 1.15 | | 0.13–4.15
| | | | Age Adjusted relative risk of death
| | | | | | | | | RR (95%CI)
| | | | Hypertension | | | | | 1.65 | | 0.86–3.16
| | | | Heart disease | | | | | 3 | | 1.47–6.12
| | | | Diabetes | | | | | 2.03 | | 0.95–4.34
| | | | Multivariate relative risk of death
| | | | Diabetes | | | | | 2.62 | | 1.19–5.77
| | | | Heart disease | | | | | 3.66 | | 1.73–7.78
Lavela, 2006^3^ | 18,372 veterans with SCI and disorders who use VA health services. | | Presence of spinal cord injury; race; mean duration of injury; level of injury, age at injury; behavioral risk factors: smoking and alcohol intake; diabetes mellitus. | Self reported diabetes with 72-item Spinal Cord Dysfunction Health Care Questionnaire (SCD-HCQ). Self reported coronary heart disease, myocardial infarction, arterial hypertension, stroke, hyperlipidemia, asthma, hepatitis, pressure sore, tooth or gum diseases; quality of care indicators; quality of life indicators.
A national cross-sectional survey of veterans with spinal cord injuries to analyze prevalence of diabetes and its complications compared to the general population. | Exclusion criteria: veterans who used non VA care, gestational diabetes, multiple sclerosis.
Time: 2003 | Control: 2003 Behavioral Risk Factor Surveillance System survey data for veteran and general population from the Centers for Disease Control and prevention.
Adjustment: age, race, marital status, duration of injury, employment, and education. | Population: 5,690 responders (rate 31%), 3,737 eligible. 6,433 general veteran group and 221,650 general population group. Males 97%; Whites 81%; mean age 60 years; 52% with paraplegic level injury; mean years after injury 24 years.
Lee, 2006^36^ | 168 patients with SCI identified in the Spinal Cord Injury Service of the Veterans Affairs Palo Alto Medical Center | | Functional status: paraplegia; tetraplegia | Absolute rates of hypertension, dyslipidemia, insulin resistance, and the presence of metabolic syndrome obtained from medical records within 6 months of the evaluation date.
Cross sectional analysis of the association between plasma homocysteine and arterial hypertension in patients with SCI. | Exclusion criteria: not reported. | | | Prevalence of hypertension in SCI patients
Time: not reported. | Population: mean age 50.27±12.8 years; mean duration of injury of 19.17±13 years; 73 (43%) had paraplegia and 95 (56%) had tetraplegia; 11% female; 62% White. | | | N=168 | | | N | | | %
Adjustment not reported | | | | Total | | | 76 | | | 45.24
| | | | Pre hypertension | | | 55 | | | 32.74
| | | | Stage 1 hypertension | | | 27 | | | 16.07
| | | | Stage 2 hypertension | | | 14 | | | 8.33

Table 3 Prevalence of cardiovascular symptoms* and hypertension depending on level on injury

Author | Sample (n) | Level of injury | Prevalence, %
CVD symptoms
Levi, 1995^30^ | 53 | Cervical injury, complete | 72
| 93 | Cervical injury, incomplete | 57
| 8 | Lumbosacral injury, complete | 62
| 47 | Lumbosacral injury, incomplete | 38
| 78 | Thoracic injury, complete | 72
| 48 | Thoracic injury, incomplete | 58
Hypertension
Imai, 1994^8^ | 244 | L2 level of injury | 2.05
| | T11-L2 level of injury | 8.61
| | T6–T10 level of injury | 2.05

* Cardiovascular symptoms included ankle and leg edema, chest pain and/or palpitations

Table 4 Prevalence and odds of diabetes in adults with SCI, able bodied veterans, and the general population^3^

Age | Prevalence in SCI, % | Prevalence in Veterans, % | Odds Ratio of Diabetes in SCI vs. Veterans | | | Prevalence in Population, % | Odds Ratio of Diabetes in SCI vs. General Population
<40 | 4.6 | 3.9 | 1.19 | 0.97 | 1.45 | 1.9 | 2.48 | 2.12 | 2.91
40–44 | 6.7 | 13.7 | 0.45 | 0.39 | 0.52 | 5 | 1.36 | 1.20 | 1.55
45–59 | 10.2 | 8 | 1.31 | 1.14 | 1.50 | 6.7 | 1.58 | 1.42 | 1.42
50–54 | 17.5 | 16.2 | 1.09 | 0.99 | 1.22 | 9.4 | 2.05 | 1.88 | 1.88
55–59 | 20.2 | 18.7 | 1.1 | 0.99 | 1.22 | 13 | 1.69 | 1.56 | 1.56
60–64 | 23.1 | 35.2 | 0.55 | 0.50 | 0.61 | 16 | 1.58 | 1.46 | 1.46
65–69 | 24.9 | 28.6 | 0.83 | 0.75 | 0.91 | 15.7 | 1.78 | 1.65 | 1.65
>70 | 26.2 | 24 | 1.12 | 1.02 | 1.23 | 15.6 | 1.92 | 1.78 | 1.78

Table 5 Relative risk of ECG abnormalities in adults with SCI compared to able-bodied controls^6^

Electrocardiogram Abnormalities | Age <65 years | Age >65 years
| Relative Risk (95% CI) | Relative Risk (95% CI)
Any ECG abnormalities | 1.01 (0.87; 1.16) | 0.81 (0.66; 0.99)
Left ventricular hypertrophy with strain | 0.47 (0.26; 0.88) | 0.48 (0.16; 1.45)
PVC | 0.39 (0.18; 0.87) | 0.70 (0.32; 1.53)
Any Q wave | 0.65 (0.47; 0.91) | 1.10 (0.74; 1.64)
Anterior Q wave | 1.11 (0.62; 2.02) | 1.11 (0.42; 2.92)
Inferior Q wave | 0.61 (0.41; 0.93) | 1.09 (0.67; 1.78)
Abnormal QTc | 1.11 (0.85; 1.45) | 0.69 (0.41; 1.14)
Left atrial abnormality | 1.51 (1.00; 2.27) | 0.46 (0.12; 1.81)
IVCD | 0.47 (0.24; 0.94) | 0.67 (0.17; 2.67)
Atrial fibrillation | 0.67 (0.25; 1.81) | 0.72 (0.30; 1.69)
ST elevation | 1.20 (1.00; 1.44) | 1.17 (0.73; 1.88)
ST depression | 1.06 (0.82; 1.36) | 0.38 (0.22; 0.66)

Bold - significant association at 95% confidence level

Table 6 Relative risk of electrocardiogram abnormalities in patients with SCI with intact sympathetic innervation to the heart (injury level T6 and below) compared to impaired sympathetic activity (injury level T5 and above)^6^

ECG Abnormalities | Relative Risk (95% CI)
Any ECG abnormalities | 0.49 (0.39; 0.62)
LVH with strain | 0.57 (0.19; 1.66)
Inferior Q wave | 1.04 (0.54; 1.99)
Anterior Q wave | 0.44 (0.16; 1.22)
Any Q wave | 0.69 (0.41; 1.15)
Left atrial abnormality | 0.13 (0.04; 0.36)
IVCD | 0.28 (0.07; 1.08)
Abnormal QTc | 0.60 (0.39; 0.94)
Atrial fibrillation | 0.19 (0.04; 0.90)
ST depression | 0.72 (0.46; 1.14)
ST elevation | 0.19 (0.12; 0.28)

Bold - significant association at 95% confidence level

Table 7 Relative risk of ECG abnormalities in patients with SCI younger vs. older than 65 years of age^6^

ECG Abnormalities | Relative Risk (95% CI)
Any ECG abnormalities | 0.56 (0.44; 0.72)
RBBB | 0.17 (0.07; 0.43)
LBBB | 0.19 (0.04; 0.93)
LVH with strain | 0.64 (0.18; 2.27)
Any Q wave | 0.32 (0.19; 0.53)
Anterior Q wave | 0.53 (0.17; 1.62)
Inferior Q wave | 0.30 (0.16; 0.57)
Abnormal QTc | 0.75 (0.42; 1.33)
Left atrial abnormality | 2.20 (0.53; 9.17)
IVCD | 0.76 (0.16; 3.55)
Atrial fibrillation | 0.15 (0.04; 0.56)
ST elevation | 1.25 (0.76; 2.06)
ST depression | 0.97 (0.53; 1.79)

Bold - significant association at 95% confidence level