# Appendix C: Data Abstraction Form

- ID of the study from PubMed or Cochrane ____________

- Number of the study _______________

- First author _____________

- Year of the publication____________

- Design of the study:

- Observational prospective

- Observational retrospective

- Case-control

Level of evidence:

Description of the target population ______________________

Description and clear definition of primary outcomes_________________

Description and clear definition of secondary outcomes__________________

Validation of the measurements of the exposure_________________

Validation of the measurements of the outcomes___________________

Process of the subject selection_______________

Adequacy of the sampling (random selection or not)_______________

Assessment of selection bias____________________

Loss of followup_________________________

Length of followup (when applicable) in months_______________

Validity of the measurements of confounding factors_________________

Appropriateness matching________________________

Appropriateness of adjustment____________________

Appropriateness of standardization_____________________

Measurement of possible effect measure modification________________

External validity of the study____________________

Years of observation, interval______________________

Number of patients selected_________________________

Number of patients analyzed________________________

Data used in the analysis____________________

Adjustment for age of the patients, years________________

Adjustment for race of the patients_______________________

Adjustment for functional status, level of injury____________________

Adjustment for socioeconomic status of the patients_________________

Adjustment for comorbidities of the patients_________________

Patient age____________________

Patient race, % of blacks________________________

Patient gender, % of females_____________________

Time after injury in years_____________________

Diagnosis of insulin resistance and diagnostic criteria of insulin resistance________

Diagnosis of metabolic syndrome__________________

Diagnosis of diabetes mellitus ______________________

Diagnosis of impaired glucose tolerance____________________

% with insulin resistance__________________

% with metabolic syndrome__________________

% with diabetes mellitus_______________________

% with glucose tolerance______________________

% with elevated cholesterol_______________________

% with elevated LDL_______________________

% with elevated TG_____________________

% with decreased HDL____________________

% with dyslipidemia_________________________

% with obesity___________________________

% with abdominal obesity_________________

Diagnosis of hypertension___________________

Proportion of fat in total body mass__________________

Proportion of abdominal fat in total body fat_____________

Waist-hip ratio________________

% of subjects with I class of obesity_________________

% of subjects with II class of obesity___________________

% of subjects with III class of obesity_________________________

Proportion of patients in the sample with upper cervical SCI______________

Proportion of patients in the sample with low cervical SCI_______________

Proportion of patients in the sample with upper thoracic SCI_____________

Proportion of patients in the sample with lower thoracic SCI_________________

Proportion of patients in the sample with lumbar SCI______________________

Proportion of patients in the sample with sacral SCI____________________

Proportion of patients in the sample with coccygeal SCI________________

Proportion of patients in the sample with tetraplegia _________________

Proportion of patients in the sample with paraplegia __________________

Functional status of the patients (definition and level)___________________

Incidence of arrhythmia, events/year in 1,000 patients with SCI___________

% of patients with SCI with arrhythmia_____________________

Incidence of heart arrest, events/year in 1,000 patients with SCI____________

% of patients with SCI with heart arrest___________________________

Incidence of congestive heart failure, events/year in 1,000 patients with SCI_______

% of patients with SCI with congestive heart failure_____________________

Incidence of coronary disease, events/year in 1,000 patients with SCI___________

% of patients with SCI with coronary disease______________________

Incidence of stroke, events/year in 1,000 patients with SCI________________

% of patients with SCI with stroke_____________________

Incidence of hypertension, events/year in 1,000 patients with SCI___________

% of patients with SCI with hypertension________________________

Incidence of chronic renal failure, events/year in 1,000 patients with SCI________

% of patients with SCI with chronic renal failure_____________________

Mean of glomerular filtration rate in ml per min_______________________

Mortality, all causes, events/year in 1,000 patients with SCI______________

% of patients with SCI who died within year of followup_______________

Cardiovascular mortality, events/year in 1,000 patients with SCI_________

% of patients with SCI who died from CVD events within year of followup_______

Relative risk of arrhythmia, 95% CI__________________

Relative risk of arrest, 95% CI_____________________

Relative risk of CHF, 95% CI_______________________

Relative risk of coronary heart disease, 95% CI_________________

Relative risk of stroke, 95% CI______________________

Relative risk of hypertension, 95% CI___________________

Relative risk of CFR, 95% CI_________________________

Relative risk of all cause mortality, 95% CI____________________

Relative risk of CVD mortality, 95% CI______________________

Number of patients with arrhythmia ________________________

Number of patients with cardiac arrest________________________

Number of patients with congestive heart failure__________________

Number of patients with coronary heart disease_____________________

Number of patients with stroke___________________________

Number of patients with hypertension_______________________

Number of patients who died from CVD______________________