# Appendix B: Exact Search Strings

Medical Subject Headings Terms and Key Words | Number of Retrieved References
“Spinal Cord Injuries” [MeSH] AND (“Cardiovascular Diseases” [MeSH] OR “Cardiology” [MeSH]) NOT review NOT letter NOT editorial NOT Case Reports
Limits: All Adult: 19+ years, Entrez Date from 1990/01/01 to 2007/07/01, English, Humans | 233
“Spinal Cord Injuries” [MeSH] AND Cardiovascular Diseases
Limits: English, Humans | 1,467
“Spinal Cord Injuries” [MeSH] AND Cardiovascular Diseases
Limits: English, Randomized Controlled Trial, Humans | 20
“Spinal Cord Injuries” [MeSH] AND Cardiovascular Diseases
Limits: English, Clinical Trial, Humans | 55
“Spinal Cord Injuries” [MeSH] AND “Cardiovascular Diseases” [MeSH]
Limits: English, Clinical Trial, Humans | 55
“Spinal Cord Injuries” [MeSH] AND “Cardiovascular Diseases” [MeSH]
Limits: English, Randomized Controlled Trial, Humans | 20
“Spinal Cord Injuries” [MeSH] AND “Cardiovascular Diseases” [MeSH]
Limits: English, Meta-Analysis, Humans | 1
“Spinal Cord Injuries” [MeSH] AND “Cardiovascular Diseases” [MeSH]
Limits: English, Humans | 1,464
“Spinal Cord Injuries” [MeSH] AND “Cardiovascular Diseases” [MeSH] AND “Insulin Resistance” [MeSH]
Limits: English, Humans | 2
“Cardiovascular Diseases” [MeSH] Limits: English, Humans | 780,975
(“Cardiovascular Diseases” [MeSH] OR “Cardiology” [MeSH]) NOT review NOT letter NOT editorial
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 402,080
(“Cardiovascular Diseases” [MeSH] OR “Cardiology” [MeSH])
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 456,995
“Spinal Cord Injuries” [MeSH] NOT review NOT Letter NOT editorial AND “Diabetes Complications” [MeSH] NOT review NOT letter NOT editorial
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 19
“Trauma, Nervous System” [MeSH] AND (“Spinal Cord” [MeSH] OR “Spinal Cord Injuries” [MeSH] OR “Spinal Cord Diseases” [MeSH]) NOT review NOT letter NOT editorial AND (“Cardiovascular Diseases” [MeSH] OR “Cardiology” [MeSH])
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 669
“Autonomic Dysreflexia” [MeSH] AND (“Cardiovascular Diseases” [MeSH]) NOT review NOT letter NOT editorial
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 17
“Autonomic Dysreflexia” [MeSH] AND (“Cardiovascular Diseases” [MeSH])
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 23
“Brown-Sequard Syndrome” [MeSH] AND (“Cardiology” [MeSH])
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 0
“Brown-Sequard Syndrome” [MeSH] AND (“Cardiovascular Diseases” [MeSH])
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 8
“Quadriplegia” [MeSH] NOT review NOT letter NOT editorial AND (“Cardiovascular Diseases” [MeSH] OR “Cardiology” [MeSH])
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 299
“Paraplegia” [MeSH] NOT review NOT letter NOT editorial AND (“Cardiovascular Diseases” [MeSH] OR “Cardiology” [MeSH])
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 587
“Spinal cord injury” AND (“Cardiovascular Diseases/epidemiology” [MeSH] OR “Cardiovascular Diseases/etiology” [MeSH] OR “Cardiovascular Diseases/prevention and control” [MeSH]) NOT review Not letter Not editorial
Limits: Adult: 19–44 years, Middle Aged: 45–64 years, Middle Aged + Aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, Humans | 259
Related Articles for PubMed (Select 16823238) | 302
Select 3 document(s) | 3
Search “Cardiovascular Diseases” [MeSH] AND “Spinal Cord Diseases” [MeSH] NOT review NOT case report NOT letter NOT editorial
Limits: All Adult: 19+ years, English, published in the last 10 years, Humans | 288
Search “Cardiovascular Diseases” [MeSH] AND “Spinal Cord Diseases” [MeSH] NOT review NOT case report NOT letter NOT editorial
Limits: All Adult: 19+ years, English, Humans | 888
Search “Cardiovascular Diseases” [MeSH] AND “Spinal Cord Diseases” [MeSH] NOT review NOT case report NOT letter NOT editorial
Limits: All Adult: 19+ years, Humans | 1,320
Search “Cardiovascular Diseases” [MeSH] AND “Spinal Cord Diseases” [MeSH]
Limits: All Adult: 19+ years, Humans | 3,040
Search “Cardiovascular Diseases” [MeSH] AND “Spinal Cord Diseases” [MeSH] | 5,414
Search “Cardiovascular Diseases” [MeSH] | 1,366,747
Search “Spinal Cord Diseases” [MeSH] | 71,345