# Appendix A: Technical Expert Panel Members and Affiliation

TEP Member | Affiliation
Yuying Chen, MD, PhD | Physical Medicine and Rehabilitation
| University of Alabama at Birmingham
David R. Gater, Jr, PhD, MD | Department of Veterans Affairs
| Hunter Holmes McGuire Medical Center
Leonard Pogach, MD | Department of Veterans Affairs
| New Jersey Health Care System
Suparna Rajan, PhD, RD | Department of Veterans Affairs
| Puget Sound Health Care System