# Appendixes

Appendix A: Technical Expert Panel Members and Affiliation

Appendix B: Exact Search Strings

Appendix C: Data Abstraction Form

Appendix D: List of Excluded Studies

Appendix E: Evidence Tables

Appendix F: Conceptual Definition of Outcomes