# Appendix F: Evidence Tables

Evidence Table 1. Characteristics of studies reporting on the effects of oral hypoglycemic agents or insulin on maternal and neonatal outcomes: randomized controlled trials

Author, year | Time period | OGTT | OGTT results (in mg/dL) | Mean age (in years) (Age range) | Race, n (%) | Weight (in kg) / BMI (in kg/m^2^), mean | Gravida/parity, mean | Treatment, N | Initial dose (fixed or escalated)
Country | | GA at diagnosis (in weeks) | | | | | | | Maximum dose
Study design | | | | | | | | | Mean dose
Insulin versus glyburide
Anjalakshi, 2006^33^ | NR | 75-gm WHO | G1: 2hr: 174.92 | G1: 27.46 | G1: Asian: 13 (100) | G1: Pre-pregnancy BMI: 25.32 | G1: NR | G1: Insulin, 13 | G1: Initial dose: 0.1 units/kg (esc)
India | | G1: 22.62 | | | | | | | Max dose: NR
RCT | | | | | | | | | Mean dose: NR
| | G2: 22.5 | G2: 2hr: 167.1* | G2: 24.9 | G2: Asian: 10 (100) | G2: Pre-pregnancy BMI: 22.82 | G2: NR | G2: Glibenclamide, 10 | G2: Initial dose: 0.625 mg (esc)
| | | | | | | | | Max dose: NR
| | | | | | | | | Mean dose: NR
Bertini, 2005^37^ | Start year: October 1, 2003 | 75-gm WHO and the Brazilian | G1: NR | G1: 28.7 | G1: NR | G1: Pre-pregnancy BMI: 27 | G1: Gravida: 2.5 | G1: Insulin, 27 | G1: Initial dose: 0.7 units/kg in the 1st trimester, 0.8 in the second, 0.9 in the third, 4 times per day (esc)
Brazil | End year: July 1, 2004 | Health Ministry | | | | | | | Max dose: NR
RCT | Planned study period: 8 months | F: 110 mg/dL | | | | | | | Mean dose: NR
| | 2hr: 140 mg/dL
| | G1: NR
| | G2: NR | G2: NR | G2: 31.2 | G2: NR | G2: Pre-pregnancy BMI: 27.5 | G2: Gravida: 3.2 | G2: Glyburide, 24 | G2: Initial dose: 5 mg, 1 time per day (esc)
| | | | | | | | | Max dose: 20mg/day
| | | | | | | | | Mean dose: NR
| | G3: NR | G3: NR | G3: 31.5 | G3: NR | G3: Pre-pregnancy BMI: 25.7 | G3: Gravida: 2.9 | G3: Acarbose, 19 | G3: Initial dose: 50 mg, 3 times per day (esc)
| | | | | | | | | Max dose: 300mg/day
| | | | | | | | | Mean dose: NR
Langer, 2000^32^ ^107^ | NR | 3hr 100-gm OGTT^†^ | G1: F: 98 | G1: 30 | G1: NR | G1: Pre-pregnancy BMI (n, % with BMI>=27.3): 132 (65) | G1: (Number of nulliparity: 59) | G1: Insulin, 203 | G1: Initial dose: 0.7 units/kg, 3 times per day (esc)
US | | F: 95 mg/dL | 1hr: 201 | | | | | | Max dose: no max dose
RCT | | G1: 25 | 2hr: 174 | | | | | | Mean dose: 85 units/day
| | | 3hr: 134
| | G2: 24 | G2: F: 97 | G2: 29 | G2: NR | G2: Pre-pregnancy BMI (n, % with BMI>=27.3): 141 (70) | G2: (Number of nulliparity: 56) | G2: Glyburide, 201 | G2: Initial dose: 2.5 mg, 1 time per day (esc)
| | | 1hr: 197 | | | | | | Max dose: 20 mg/day
| | | 2hr: 174 | | | | | | Mean dose: 9 mg/day
| | | 3hr: 140
Insulin versus insulin lispro
Jovanovic, 1999^36^ | NR | 100-gm, Carpenter and Coustan criteria | G1: NR | G1: 29.8 | G1: C: 0 (0) | G1: Pre-pregnancy weight: 78.5 | G1: Gravida: 2.4 | G1: Regular human insulin, 23 | G1: Initial dose: 0.7 units/kg, 3 + 2 NPH times per day (esc)
US | | G1: 25.6 | | | Hisp: 23 (100) | Pre-pregnancy BMI: 33.3 | Parity: 1.7 | | Max dose: NR
RCT | | | | | | | | | Mean dose: NR
| | G2: 27.3 | G2: NR | G2: 34.2 | G2: C: 2 (11) | G2: Pre-pregnancy weight: 76.3 | G2: Gravida: 1.8 | G2: Insulin lispro, 19 | G2: Initial dose: 0.7 units/kg, 3 + 2 NPH times per day (esc)
| | | | | Hisp: 17 (89) | Pre-pregnancy BMI: 31.5 | Parity: 1.4 | | Max dose: NR
| | | | | | | | | Mean dose: NR
Mecacci, 2003^34^ | Start year: June 1999 | 100-gm, Carpenter and Coustan criteria | G1: F: 91 | G1: (28–41) (median 35) | G1: C: 24 (100) | G1: Pre-pregnancy weight: (Median: 60.5) | G1: Parity: (median 1 (range 0–1)) | G1: Regular human insulin, 24 | G1: Initial dose: 1 unit/10 gms of carbohydrate in each meal, 3 times per day (esc)
Italy | End year: Dec 2000 | G1: median 28 (26–32) | 1hr: 197 | | | Pre-pregnancy BMI: (Median: 22.3) | | | Max dose: NR
RCT | | | 2hr: 189 | | | | | | Mean dose: 34.3 units/day
| | | 3hr: 138
| | G2: median 28 (25–32) | G2: F: 92 | G2: (24–40) (median 34.5) | G2: C: 25 (100) | G2: Pre-pregnancy weight: (Median: 61.4) | G2: Parity: (median 1 (range 0–2)) | G2: Insulin lispro, 25 | G2: Initial dose: 1 unit/10 gms of carbohydrate in each meal, 3 times per day (esc)
| | | 1hr: 193 | | | Pre-pregnancy BMI: (Median: 21.5) | | | Max dose: NR
| | | 2hr: 170 | | | | | | Mean dose: 35.1 units/day
| | | 3hr: 126
Insulin versus insulin
Nachum, 1999^35^ | Start year: 1993 | 100-gm, O'sullivan or NDDG | G1: NR | G1: 33 | G1: NR | G1: Pre-pregnancy weight: 72 | G1: Gravida: 3.4 | G1: Insulin twice daily, 136 | G1: Initial dose: NR, 2 times per day
Israel | End year: 1997 | G1: 28 | | | | Pre-pregnancy BMI: 27.8 | | | Max dose: NR
RCT | Planned study period: 48 months | | | | | | | | Mean dose: NR
| | G2: 27.4 | G2: NR | G2: 33 | G2: NR | G2: Pre-pregnancy weight: 73 | G2: Gravida: 3.5 | G2: Insulin four times daily, 138 | G2: Initial dose: NR, 4 times per day
| | | | | | Pre-pregnancy BMI: 27.9 | | | Max dose: NR
| | | | | | | | | Mean dose: NR
Poyhonen-Alho, 2002^31^ | NR | 2hr, 75-gm | G1: NR | G1: NR | G1: NR | G1: NR | G1: NR | G1: Short-acting insulin, 11 | G1: Initial dose: 4+6+4 IU, 3 times per day (before breakfast, lunch, dinner) (esc)
Finland | | F: 4.8 mmol/L | | | | | | | Max dose: 16.8
RCT | | 1hr: 10 mmol/L | | | | | | | Mean dose: NR
| | 2hr: 8.7 mmol/L
| | G1: (24–28)
| | G2: NR | G2: NR | G2: NR | G2: NR | G2: NR | G2: NR | G2: Long-acting insulin, 12 | G2: Initial dose: 14 IU, 1 time per day (morning) (esc)
| | | | | | | | | Max dose: 19.5
| | | | | | | | | Mean dose: NR
Diet versus insulin
Thompson, 1990^30^ | Start year: 1985 | 100-gm, O'sullivan or NDDG | G1: F: 101 | G1: 26 | G1: NR | G1: Post-pregnancy weight: 200 lb | G1: Gravida: 2.5 | G1: Diet, 50 | G1: Initial dose: 35 kilocalories/kg ideal body weight
US | End year: 1988 | G1: NR | | | | | Parity: 1.3
RCT
| | G2: NR | G2: F: 101 | G2: 27 | G2: NR | G2: Post-pregnancy weight: 192 lb | G2: Gravida: 3 Parity: 1.4 | G2: Diet and insulin, 45 | G2: Initial dose: 20 units NPH + 10 units RI units, 1 time per day (fixed)
| | | | | | | | | Max dose: NR
| | | | | | | | | Mean dose: NR

* This is the 2 hr PG status after 2 weeks of diet, not the 2hr PG after 75-gm OGTT.

† Only used FBG to determine treatment and eligibility for study.

Asian = Asian or Asian American; BMI = body mass index; C = Caucasian; dL = deciliter; esc = escalated; F = fasting; FBG = fasting blood glucose; G = group; GA = gestational age; gm = gram; Hisp = Hispanic; hr = hour; IU = international units; kg = kilogram; L = liter; lb = pound; m = meter; mg = milligram; mmol = millimole; NDDG = National Diabetes Data Group; NPH = neutral protamine Hagedorn; NR = not reported; OGTT = oral glucose tolerance test; PG = plasma glucose; RCT = randomized controlled trial; RI = regular insulin; US = United States; WHO = World Health Organization

Evidence Table 2. Effects of oral hypoglycemic agents or insulin on maternal outcomes: randomized controlled trials

Author, year | Treatment, N | Operative vaginal delivery, n (%) | Pre-eclampsia, n (%) | Cesarean delivery, n (%) | Weight, mean | Glycemic control during pregnancy, mean | Hypoglycemia, n (%) | Intention to treat analysis
Insulin versus glyburide
Anjalakshi, 2006^33^ | G1: Insulin, 13 | | | | | 2 hr PG at entry and before confinement (mg/dL) | | NR
| | | | | | Baseline: 174.92 (sd: 31.05)
| | | | | | Final: 93 (sd: 9.75)
| G2: Glibenclamide, 10 | | | | | 2 hr PG at entry and before confinement (mg/dL)
| | | | | | Baseline: 167.1 (sd: 22.97)
| | | | | | Final: 95.29 (sd: 7.41)
Bertini, 2005^37^ | G1: Insulin, 27 | | | Total cesarean deliveries: 12 (44) | Maternal weight (kg) | | Requiring hospital admission: 0 (0) | Y
| | | | | Mean difference from baseline: 11.5 (sd: 3.8)
| G2: Glyburide, 24 | | | Total cesarean deliveries: 12 (50) | Maternal weight (kg) | | Requiring hospital admission: 0 (0)
| | | | | Mean difference from baseline: 10 (sd: 5.2)
| G3: Acarbose, 19 | | | Total cesarean deliveries: 10 (52) | Maternal weight (kg) | | Requiring hospital admission: 0 (0)
| | | | | Mean difference from baseline: 10.6 (sd: 3.2)
| | | | | p = 0.46*
Langer, 2000^32^ | G1: Insulin, 203 | | 12 (6) | Total cesarean deliveries: 49 (24) | | FBG (mg/dL) | Fsg < 40 mg/dL: 41 (20) | Y
| | | | | | Baseline: 108 (sd: 26)
| | | | | | Final: 96^†^ (sd: 16)
| | | | | | Pre-prandial glucose (mg/dL)
| | | | | | Baseline: 107 (sd: 23)
| | | | | | Final: 97^†^ (sd: 14)
| | | | | | 2 hr PPG (mg/dL)
| | | | | | Baseline: 129 (sd: 27)
| | | | | | Final: 112^†^ (sd: 15)
| | | | | | Combined glucose (mg/dL)
| | | | | | Baseline: 116^‡^ (sd: 22)
| | | | | | Final: 105 (sd: 18)
| G2: Glyburide, 201 | | 12 (6) | Total cesarean deliveries: 46 (23) | | FBG (mg/dL) | Fsg < 40 mg/dL: 4 (2)
| | | | | | Baseline: 104 (sd: 25) | p = 0.03^¶^
| | | | | | p = 0.12^¶^
| | | | | | Final: 98^†^ (sd: 13)
| | | | | | p = 0.17^¶^
| | | | | | Pre-prandial glucose (mg/dL)
| | | | | | Baseline: 104 (sd: 20)
| | | | | | p = 0.16^¶^
| | | | | | Final: 95^†^ (sd: 15)
| | | | | | p = 0.17^¶^
| | | | | | 2 hr PPG (mg/dL) Baseline: 130 (sd: 25)
| | | | | | p = 0.69^¶^
| | | | | | Final: 113^†^ (sd: 22)
| | | | | | p = 0.6^¶^
| | | | | | Combined glucose (mg/dL)
| | | | | | Baseline: 114^‡^ (sd: 19)
| | | | | | p = 0.33^¶^
| | | | | | Final: 105 (sd: 16)
| | | | | | p = 0.99^¶^
Insulin versus insulin lispro
Jovanovic, 1999 ^36^ | G1: Regular human insulin, 23 | | | Total cesarean deliveries: 6 (27.27) | | HbA1c (%) | Fsg < 55 mg/dL: | NR
| | | | | | Baseline: 5.24 (sd: 0.09) | mean % hypoglycemic episodes of all blood glucose determinations: 2.2
| | | | | | Final: 5.16 (sd: 0.12)
| | | | | | Mean difference from baseline: 0.07
| G2: Insulin lispro, 19 | | | Total cesarean deliveries: 7 (36.84) | | HbA1c (%) | Fsg < 55 mg/dL: mean % hypoglycemic episodes of all blood glucose determinations: 0.88
| | | | | | Baseline: 5.47 (sd: 0.09)
| | | | | | Final: 5.12 (sd: 0.11)
| | | | | | Mean difference from baseline: 0.35
Mecacci, 2003 ^34^ | G1: Regular human insulin, 24 | | | Cesarean delivery for CPD: 2 (8) | | Pre-prandial glucose (mg/dL) | | N
| | | | Total cesarean deliveries: 6 (25) | | Mean: 74.3^§^ (sd: 8.6)
| | | | | | 1 hour PPG (mg/dL)
| | | | | | Mean: 88^§^ (sd: 11)
| | | | | | 2 hour PPG (mg/dL)
| | | | | | Mean: 97.9^§^ (sd: 12.5)
| G2: Insulin lispro, 25 | | | Cesarean delivery for CPD: 1 (4) | | Pre-prandial glucose (mg/dL)
| | | | p > 0.05^‖^ | | Mean: 73.4^§^ (sd: 8.1)
| | | | Total cesarean deliveries: 7 (28) | | p > 0.05^‖^
| | | | p > 0.05^‖^ | | 1 hour PPG (mg/dL)
| | | | | | Mean: 108.4^§^ (sd: 10.7)
| | | | | | p < 0.001^‖^
| | | | | | 2 hour PPG (mg/dL)
| | | | | | Mean: 93.6^§^ (sd: 11.1)
| | | | | | p > 0.05^‖^
Insulin versus insulin
Nachum, 1999 ^35^ | G1: Insulin twice daily, 136 | | | Total cesarean deliveries: 52 (38) | Maternal weight gain (kg) | Combined glucose (mmol/L) | Severe hypoglycemia requiring help from another person: 1 (0.7) | NR
| | | | | Mean difference from baseline: 11.4 (sd: 3.5) | Final mean: 5.6 (sd: 0.48)
| | | | | | HbA1c (%)
| | | | | | Final: 5.8 (sd: 1)
| G2: Insulin four times daily, 138 | | | Total cesarean deliveries: 54 (39) Risk difference: 0 | Maternal weight gain (kg) | Combined glucose (mmol/L) | Severe hypoglycemia requiring help from another person: 1 (0.7)
| | | | | Mean difference from baseline: 10.7 (sd: 3.6) | Final: 5.42 (sd: 0.54)
| | | | | | HbA1c (%)
| | | | | | Final: 5.5 (sd: 1)
Diet versus insulin
Thompson, 1990 ^30^ | G1: Diet, 50 | | | Total cesarean deliveries: 8 (23.53) | | FBG (mg/dL) | | NR
| | | | | | Baseline: 95 (sd: 13)
| | | | | | Final: 79.7 (sd: 11)
| G2: Diet and insulin, 45 | | | Total cesarean deliveries: 8 (23.53) | | FBG (mg/dL)
| | | | | | Baseline: 96 (sd: 12)
| | | | | | Final: 81.3 (sd: 8)

* Comparing G1 to G2 to G3.

† Mean values throughout pregnancy.

‡ Mean glucose 1 week prior to treatment assignment.

¶ Comparing G1 to G2.

§ Mean from diagnosis of GDM to 38 weeks.

‖ Comparing G1 to G2 to G3, where G3 is a nondiabetic control group whose data is not shown.

CPD = cephalopelvic disproportion; dL = deciliter; FBG = fasting blood glucose; fsg = finger stick glucose; G = group; HbA1c = Hemoglobin A1c; hr = hour; kg = kilograms; mg = milligrams; N = no; NR = not reported; PG = plasma glucose; PPG = postprandial glucose; sd = standard deviation; Y = yes

Evidence Table 3. Grading of the body of evidence of the effects of oral hypoglycemic agents or insulin on maternal or neonatal outcomes (KQ1)

| Maternal outcomes
| Insulin versus glyburide | Insulin versus insulin lispro | Diet or insulin versus insulin
[underlined: Quantity of evidence:] | 7 | 2 | 3
Number of studies
Total number of patients studied | 1310 | 91 | 392
[underlined: Quality and consistency of evidence:] | Medium | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -2 | -2 | -2
Did the studies have important inconsistency? (-1) | -1 | -1 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | -1 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | -1 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | +1 | +1 | +1
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low | Very low
| Neonatal outcomes
| Insulin versus glyburide | Insulin versus insulin lispro | Diet or insulin versus insulin
[underlined: Quantity of evidence:] | 7 | 2 | 3
Number of studies
Total number of patients studied | 1310 | 91 | 392
[underlined: Quality and consistency of evidence:] | Medium | High | High
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -2 | -2 | -2
Did the studies have important inconsistency? (-1) | -1 | -1 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? [underlined: Reminder: we're looking for head to head comparisons of different diabetes meds to get full credit for directness in addressing our question.] | -1 | -1 | -1
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0/-1 | 0 | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | +1 | +1 | +1
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low | Very low

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely to] change the estimate; very low = any estimate of effect is very uncertain.

Evidence Table 4. Effects of oral hypoglycemic agents or insulin on neonatal outcomes: randomized controlled trials

Author, year | Treatment, N | Hypoglycemia, n (%) | Hyperbilirubinemia, n (%) | Macrosomia, n (%) | LGA, n (%) | SGA, n (%) | Mortality, n (%) | Other outcome, n (%) | Birth weight, mean
Insulin versus glyburide
Anjalakshi, 2006^33^ | G1: Insulin, 13 | | | | | | | | 2.6 kg (sd: 0.43)
| G2: Glibenclamide, 10 | | | | | | | | 2.72 kg (sd: 0.34
Bertini, 2005^37^ | G1: Insulin, 27 | Capillary glucose < 40 mg/dL: 1 (4) | | Birth weight > 4000 gm: 0 (0) | Percentile weight > 90: 1 (4) | Criteria NR: 2 (7) | Perinatal mortality: 0 (0) | | 3151.2 gm (sd: 407.2)
| G2: Glyburide, 24 | Capillary glucose < 40 mg/dL: 8 (33) | | Birth weight > 4000 gm: 4 (16) | Percentile weight > 90: 6 (25) | Criteria NR: 0 (0) | Perinatal mortality: 0 (0) | | 3395.6 gm (sd: 524.4)
| G3: Acarbose, 19 | Capillary glucose < 40 mg/dL: 1 (5) | | Birth weight > 4000 gm: 0 (0) | Percentile weight > 90: 2 (10) | Criteria NR: 0 (0) | Perinatal mortality: 0 (0) | | 3242.6 gm (sd: 400.6)
| | p = 0.006* | | | p = 0.073* | | | | p = 0.15*
Langer, 2000 ^32^ | G1: Insulin, 203 | Two consecutive blood glucose < 40 mg/dL: 12 (6) | Serum bilirubin > 12 mg/dL: 8 (4) | Birth weight > 4000 gm: 9 (4) | Percentile weight > 90: 26 (13) | | Perinatal mortality: 2 (1) | Congenital malformation: 4 (2) | 3194 gm (sd: 598)
| | | | | | | | NICU admission: 14 (7)
| G2: Glyburide, 201 | Two consecutive blood glucose < 40 mg/dL: 18 (9) | Serum bilirubin > 12 mg/dL: 12 (6) | Birth weight > 4000 gm: 14 (7) | Percentile weight > 90: 24 (12) | | Perinatal mortality: 2 (1) | Congenital malformation: 5 (2) | 3256 gm (sd: 543)
| | p = 0.25^†^ | p = 0.36^†^ | p = 0.26^†^ | p = 0.76^†^ | | p = 0.99^†^ | p = 0.74^†^ | p = 0.28^†^
| | | | | | | | NICU admission: 12 (6)
| | | | | | | | p = 0.68^†^
Jovanovic, 1999 ^36^ | G1: Regular human insulin, 23 | | | | | | | | 3169 gm (se: 78)
| G2: Insulin lispro, 19 | | | | | | | | 3098 gm (se: 202)
Mecacci, 2003 ^34^ | G1: Regular human insulin, 24 | | | | Percentile weight >= 90: 3 (12) | Percentile weight <= 10: 1 (4) | | | 3270.8 gm (sd: 389.2)
| G2: Insulin lispro, 25 | | | | Percentile weight >= 90: 2 (8) | Percentile weight <= 10: 1 (4) | | | 3320.8 gm (sd: 246.6)
| | | | | p > 0.05^‡^ | p > 0.05^‡^ | | | p > 0.05^†^
Nachum, 1999 ^35^ | G1: Insulin twice daily, 136 | Plasma glucose < 1.9 mmol/l in term infants or < 1.4 mmol/l in preterm infants at least on two different occasions during first 48 hours of life: 8 (6) | Serum bilirubin > 205 mmol/l at >= 34 weeks of gestation or > 137 mmol/l at < 34 weeks of gestation: 29 (21) | Birth weight > 4000 gm: 26 (19) | Percentile weight > 90: 41 (30) | Percentile weight < 10: 7 (5) | Perinatal mortality: 1 (1) | Congenital malformation, fatal, requiring surgery, or having significant psychological effects on fetus in later life: 2 (2)
| | | | | | | | RDS, hyaline membrane disease: 0 (0.00)
| | | | | | | | birth trauma, peripheral nerve injury or bone fracture: 3 (2)
| G2: Insulin four times daily, 138 | Plasma glucose < 1.9 mmol/l in term infants or < 1.4 mmol/l in preterm infants at least on two different occasions during first 48 hours of life: 1 (1) | Serum bilirubin > 205mmol/l at >= 34 weeks of gestation or > 137 mmol/l at < 34 weeks of gestation: 15 (11) | Birth weight > 4000 gm: 22 (16) | Percentile weight > 90: 36 (26) | Percentile weight < 10: 4 (3) | Perinatal mortality: 0 (0.00) | Congenital malformation, fatal, requiring surgery, or having significant psychological effects on fetus in later life: 1 (1)
| | | | | | | | RDS, hyaline membrane disease: 1 (1)
| | | | | | | | birth trauma, peripheral nerve injury or bone fracture: 2 (1)
Poyhonen-Alho, 2002 ^31^ | G1: Short-acting insulin, 11 | NR: 0 (0.00) | NR: 3 (27.27) | (Greater than 2 sd of the mean birth weight = 3079 ± 722): 0 (0.00) | | | | Birth trauma (nerve palsy): 0 (0.00)
| G2: Long-acting insulin, 12 | NR: 1 (8.33) | NR: 3 (25.00) | (Greater than 2 sd of the mean birth weight = 3079 ± 722): 4 (33.33) | | | | Birth trauma (nerve palsy): 1 (8.33)
| | | | p: 0.05^†^
Diet versus insulin
Thompson, 1990 ^30^ | G1: Diet, 50 | Plasma glucose < 30 mg/dL: 5 (14.71) | Serum bilirubin > 10 mg/dL: 0 (0.00) | Birth weight > 4000 gm: 9 (26.47)^¶^ | | | | | 3584 gm (sd: 543)
| G2: Diet and insulin, 45 | Plasma glucose < 30 mg/dL: 6 (17.65) | Serum bilirubin > 10 mg/dL: 0 (0.00) | Birth weight > 4000 gm: 2 (5.88)^§^ | | | | | 3170 gm (sd: 522)

* Comparing G1 to G2 to G3.

† Comparing G1 to G2.

‡ Comparing G1 to G2 to G3, where G3 is a nondiabetic control group, whose data is not shown.

¶ Macrosomia in mothers with delivery weight<2001b (N=22 in both groups): 0. Macrosomia in mothers with delivery weight>=2001b (N=12 in both groups): 9.

§ Macrosomia in mothers with delivery weight<2001b (N=22 in both groups): 0. Macrosomia in mothers with delivery weight>=2001b (N=12 in both groups): 2.

dL = deciliter; G = group; gm = gram; kg = kilogram; l = liter; LGA = large for gestational age; mg = milligram; mmol = millimole; NICU = neonatal intensive care unit; NR = not reported; RDS = respiratory distress syndrome; SGA = small for gestational age; sd = standard deviation

Evidence Table 5. Quality of the studies reporting on the effects of oral hypoglycemic agents or insulin on maternal and neonatal outcomes: randomized controlled trials

Author, year | Randomized | Randomization scheme described | Double blinded | Blinding described | Withdrawals described | Quality score*
Anjalakshi, 2006^33^ | • | | | | | 1
Bertini, 2005^37^ | • | • | | | • | 3
Langer, 2000^32^ | • | • | | | | 2
Jovanovic, 1999^36^ | • | • | | | • | 3
Mecacci, 2003^34^ | • | | | | • | 2
Nachum, 1999^35^ | • | • | | | | 2
Poyhonen-Alho, 2002^31^ | • | | | | | 1
Thompson, 1990^30^ | • | • | | | • | 3

• = Yes;

blank space = No/Not reported

* Total quality score calculated using the Jadad^22^ criteria.

Evidence Table 6. Characteristics of studies reporting on the effects of oral hypoglycemic agents or insulin on maternal and neonatal outcomes: nonrandomized controlled trials and observational studies

Author, year | Time period | OGTT | OGTT results (in mg/dL) | Mean age (in years) (Age range) | Race, n (%) | Weight (in kg) / BMI (in kg/m^2^), mean | Gravida/parity, mean | Treatment, N | Initial dose (fixed or escalated)
Country | | GA at diagnosis (in weeks) | | | | | | | Maximum dose
Study design | | | | | | | | | Mean dose
Jacobson, 2005^48^ | Start year: 1999 | 100-gm O'sullivan or NDDG | G1: | G1: 32.1 | G1: AA: 10 (4) | G1: 1^st^ documented BMI during pregnancy: 31.9 | G1: (number of nulliparous women: 91 (34%)) | G1: Insulin in 1999-2000, 268 | G1: Initial dose: NR (esc)
US | End year: 2002 | G1: 26.3 | F: 105 | | C: 116 (43) | | | | Max dose: no maximum
Cohort | | | 1hr: 223 | | Asian: 64 (24) | | | | Mean dose: 34.4 units*
| | | 2hr: 197 | | Hisp: 66 (25)
| | | 3hr: 140
| | G2: 25.5 | G2: | G2: 32.8 | G2: AA: 9 (4) | G2: 1^st^ documented BMI during pregnancy: 30.6 | G2: (number of nulliparous women: 78 (33%)) | G2: Glyburide in 2001-2002, 236 | G2: Initial dose: 2.5 mg, 1 time per day (esc)
| | | F: 102 | | C: 65 (28) | | | | Max dose: 20 mg/day
| | | 1hr: 220 | | Asian: 88 (37) | | | | Mean dose: 5.6 mg^†^
| | | 2hr: 195 | | Hisp: 56 (24)
| | | 3hr: 137
| | G3: stated similar to G2 | G3: | G3: stated similar to G2 | G3: AA: stated similar to G2 | G3: 1^st^ documented BMI during pregnancy: 33.9 | G3: (number of nulliparous women: stated similar to G2) | G3: Insulin in 2001-2002, 80 | G3: Initial dose: NR (esc)
| | | F: 109 | | C: stated similar to G2 | | | | Max dose: no maximum
| | | 1hr: NR | | Asian: NR (24) | | | | Mean dose: NR
| | | 2hr: NR | | Hisp: stated similar to G2
| | | 3hr: NR
Conway, 2004^47^ | Start year: Dec 2000 | 100-gm OGTT using 2003 ADA criteria | G1: | G1: 30.3 | G1: NR | G1: Pre-pregnancy BMI: NR (stated similar between groups) | G1: Parity: 2.2 | G1: Glyburide failure, 12 | G1: Initial dose: same for glyburide as G2; for insulin was 0.7 to 1.0 (esc)
US | End year: July 2003 | F: 95 mg/dL | F: 115 | | | | | | Max dose: no maximum for insulin, max glyburide dose was 20 mg
Cohort | | 1hr: 180 mg/dL | 1hr: 230 | | | | | | Mean dose: NR
| | 2hr: 155 mg/dL | 2hr: 204
| | 3hr: 140 mg/dL | 3hr: 176
| | G1: 20; 23.3 (at time of initiation of glyburide)
| | G2: 18.4; 28.7 (at initiation of glyburide-p < 0.05) | G2: | G2: 31.3 | G2: NR | G2: Pre-pregnancy BMI: NR (stated similar between groups) | G2: Parity: 1.8 | G2: Glyburide success, 63 | G2: Initial dose: 2.5 mg, 1 time per day (esc)
| | | F: 102 | | | | | | Max dose: 20 mg (10 mg bid)
| | | 1hr: 205 | | | | | | Mean dose: NR
| | | 2hr: 169
| | | 3hr: 133
Chmait, 2004^45^ | Start year: 2000 | 100-gm Carpenter and Coustan criteria | G1: | G1: 31 | G1: Hisp: 9 (69) | G1: NR | G1: (Nulliparity: 1 (7.7%)) | G1: glyburide failure (glyburide + diet + insulin OR insulin + diet), 13 | G1: Initial dose: glyburide starting dose same as G2; insulin dosing based on weeks of gestation;^‡^ 3 times per day (esc)
US | End year: 2002 | G1: 20 | F: 105 | | non-Hispanic: 4 (31) | | | | Max dose: no maximum on insulin, max of 20 mg daily (10 mg bid of glyburide)
Cohort | | | 1hr: 206 | | | | | | Mean dose: NR
| | | 2hr: 192
| | | 3hr: 128
| | G2: 27.3 | G2: | G2: 32 | G2: Hisp: 51 (91) | G2: NR | G2: (Nulliparity: 8 (14.3%)) | G2: glyburide success (glyburide + diet), 56 | G2: Initial dose: 2.5 to 5 mg, 1 time per day (esc)
| | | F: 94 | | non-Hispanic: 5 (9) | | | | Max dose: 20 mg daily (10 mg bid)
| | | 1hr: 199 | | | | | | Mean dose: NR
| | | 2hr: 169
| | | 3hr: 126
Yogev, 2004^46^ | Start year: 2001 | 100-gm Carpenter and Coustan criteria | G1: | G1: 26.4 | G1: NR | G1: Pre-pregnancy BMI: 26 | G1: (Nulliparity: 9 (33%)) | G1: Diet, 27 | G1:NA
US | End year: 2003 | G1: NR | F: 96
Non-RCT | Planned study period: 2 years | G2: NR | G2: | G2: 28.1 | G2: NR | G2: Pre-pregnancy BMI: 27.6 | G2: (Nulliparity: 8 (27%)) | G2: Insulin, 30 | G2: Initial dose: 0.7 units/kg, 3 times per day (esc)
| | | F: 99 | | | | | | Mean dose: 72 units/day
| | G3: NR | G3: | G3: 28.3 | G3: NR | G3: Pre-pregnancy BMI: 27.5 | G3: (Nulliparity: 7 (28%)) | G3: Glyburide, 25 | G3: Initial dose: 2.5 mg, 1 time per day (esc)
| | | F: 98 | | | | | | Max dose: 20 mg
| | | | | | | | | Mean dose: 8 mg/day
Rochon, 2006^49^ | Start year: 2002 | 100-gm Carpenter and Coustan criteria | G1: | G1: 31.3 | G1: | G1: BMI at 1^st^ prenatal visit: 32.2 | G1: (Multiparous: 18 (86%)) | G1: Glyburide failure (NPH and regular insulin), 21 | G1: Initial dose: glyburide starting dose same as G2; starting dose for insulin not reported, 3 times per day (esc)
US | End year: 2005 | G1: 24 | F: 107 | | AA: 6 (29) | | | | Mean dose: NR
Cohort | Planned study period: 30 months | | 1hr: 223 | | C: 1 (5)
| | | 2hr: 189 | | Asian: 2 (10)
| | | 3hr: 114 | | Hisp: 12 (57)
| | G2: 26 | G2: | G2: 30.5 | G2: | G2: BMI at 1^st^ prenatal visit: 31.5 | G2: (Multiparous: 56 (70%) | G2: Glyburide success (glyburide + diet), 80 | G2: Initial dose 2.5 to 5 mg, 1 time per day (esc)
| | | F: 102 | | AA: 24 (30) | | | | Max dose: 20 mg daily (10 mg bid)
| | | 1hr: 200 | | C: 1 (1) | | | | Mean dose: NR
| | | 2hr: 179 | | Asian: 8 (10)
| | | 3hr: 138 | | Hisp: 47 (59)

* Only available for 249 women

† Only available for 229 women

‡ Insulin dose for 1 to 18 weeks gestation was 0.7 units/kg; for 18 to 26 weeks gestation was 0.8 units/kg; for 26 to 36 weeks gestation used 0.9 units/kg; and for 36 to 40 weeks gestation was 1.0 units/kg.

AA = African American; ADA = American Diabetes Association; Asian = Asian or Asian American; bid = twice daily; BMI = body mass index; C = Caucasian; dL = deciliter; esc = escalated; F = fasting; G = group; GA = gestational age; gm = gram; Hisp. = Hispanic; hr = hour; kg = kilogram; mg = milligram; NA = not applicable; NDDG = National Diabetes Data Group; NR = not reported; OGTT = oral glucose tolerance test; RCT = randomized controlled trial; US = United States

Evidence Table 7. Effects of oral hypoglycemic agents or insulin on maternal outcomes: non-randomized controlled trials and observational studies

Author, year | Treatment, N | Operative vaginal delivery, n (%) | Pre-eclampsia, n (%) | Cesarean delivery, n (%) | Weight, mean | Glycemic control during pregnancy, mean | Hypoglycemia, n (%)
Jacobson, 2005^48^ | G1: Insulin in 1999-2000, 268 | 15 (6) | 16 (6) | Total cesarean deliveries: 94 (36) | | FBG (mg/dL) | Fsg < 60 mg/dL:
| | | OR: ref | | | Baseline: 105.4 (sd: 12.9) | Mean #: 19
| | | | | | Final: 97.7 (sd: 12.2) | Total number of plasma glucose values measured: 22764
| | | | | | 1 hour PPG (mg/dL)
| | | | | | Baseline: 222.8 (sd: 28.9)
| | | | | | Final: 137.8 (sd: 23.6)
| | | | | | 2 hour PPG (mg/dL)
| | | | | | Baseline: 197.4 (sd: 33.6)
| | | | | | Final: 118.8 (sd: 19.6)
| G2: Glyburide in 2001-2002, 236 | 12 (5) | 28 (12) | Total cesarean deliveries: 91 (39) | | FBG (mg/dL) | Fsg < 60 mg/dL:
| | | OR: 2.32 (95% CI: 1.17–4.63) | | | Baseline: 102.4 (sd: 14.2) | Mean #: 50
| | | | | | p = 0.005* | Total number of plasma glucose values measured: 24975
| | | | | | Final: 90.2 (sd: 12.7)
| | | | | | p < 0.001*
| | | | | | 1 hour PPG (mg/dL)
| | | | | | Baseline: 220 (sd: 27.2)
| | | | | | p = 0.48*
| | | | | | Final: 131.4 (sd: 23.3)
| | | | | | p < 0.001*
| | | | | | 2 hour PPG (mg/dL)
| | | | | | Baseline: 194.7 (sd: 32.1)
| | | | | | p = 0.44*
| | | | | | Final: 117.6 (sd: 23.2)
| | | | | | p < 0.05*
Chmait, 2004^45^ | G1: glyburide failure (glyburide + diet + insulin OR insulin + diet), 13 | | | Elective cesarean delivery: 1 (7.69) | | Fasting glucose^†^ (mg/dL)
| | | | total cesarean deliveries: 5 (38) | | Mean: 114 (sd: 17)
| | | | | | 1 hour PPG^†^ (mg/dL)
| | | | | | Mean: 145 (sd: 20)
| G2: glyburide success (glyburide + diet), 56 | | | Elective cesarean delivery: 4 (7.14) | | Fasting glucose^†^ (mg/dL)
| | | | total cesarean deliveries: 19 (34) | | Mean: 88 (sd: 11)
| | | | p > 0.05* | | p < 0.001*
| | | | | | 1 hour PPG^†^ (mg/dL)
| | | | | | Mean: 124 (sd: 12)
| | | | | | p < 0.001*
Yogev, 2004^46^ | G1: Diet, 27 | | | | | FBG (mg/dL) | Fsg < 50 mg/dL, symptoms, 30 or more consecutive minutes of glucose determination less than 50 mg/dL, detected only by the CGMS without patient awareness: 0 (0)
| | | | | | Baseline: 96 (sd: 21)
| | | | | | Final: 99 (sd: 13)
| G2: Insulin, 30 | | | | | FBG (mg/dL) | Fsg < 50 mg/dL, symptoms, 30 or more consecutive minutes of glucose determination less than 50 mg/dL, detected only by the CGMS without patient awareness: 19 (63)
| | | | | | Baseline: 99 (sd: 23) | OR: 4.4 (95% CI: 1.4–13.9)
| | | | | | Final: 104 (sd: 15) | p = 0.009^‡^
| G3: Glyburide, 25 | | | | | FBG (mg/dL) | Fsg < 50 mg/dL, symptoms, 30 or more consecutive minutes of glucose determination less than 50 mg/dL, detected only by the CGMS without patient awareness: 7 (28)
| | | | | | Baseline: 98 (sd: 27) | OR: ref
| | | | | | p = 0.17^¶^
| | | | | | Final: 105 (sd: 14)
| | | | | | p = 0.24^¶^
Rochon, 2006^49^ | G1: Glyburide failure (NPH and regular insulin), 21 | | | 9 (43)
| G2: Glyburide success (glyburide + diet), 80 | | | 30 (38)

* Comparing G1 to G2

† During treatment with glyburide

‡ Comparing G1 to G2 to G3

¶ Comparing G2 to G3

CGMS = continuous glucose monitoring system; CI = confidence interval; dL = deciliter; FBG = fasting blood glucose; fsg = finger stick glucose; G = group; mg = milligrams; NPH = Neutral Protamine Hagedorn; OR = odds ratio; PPG = postprandial glucose; ref = reference group; sd = standard deviation

Evidence Table 8. Effects of oral hypoglycemic agents or insulin on neonatal outcomes: non-randomized controlled trials and observational studies

Author, year | Treatment, N | Hypoglycemia, n (%) | Hyperbilirubinemia, n (%) | Macrosomia, n (%) | LGA, n (%) | SGA, n (%) | Mortality, n (%) | Other outcome, n (%) | Birth weight, mean
Jacobson, 2005^48^ | G1: Insulin in 1999-2000, 268 | ICD-9-CM codes: 73 (27) | Serum bilirubin > 12 mg/dL within first 7 days of birth: 58 (22) | Birth weight > 4000 gm: 64 (24) | Percentile weight > 90: 63 (24) | Percentile weight < 10: 18 (7) | | NICU admission: 65 (24) | 3599 gm (sd: 650)
| | OR: ref | OR: ref | OR: ref | OR: ref | OR: ref | | OR: ref
| | | | | | | | birth trauma, claims data/ICD-9 codes, total birth injuries: 3 (1)
| | | | | | | | congenital malformation, claims data/ICD-9 codes: 4 (2)
| G2: Glyburide in 2001-2002, 236 | ICD-9-CM codes: 72 (31) | Serum bilirubin > 12 mg/dL within first 7 days of birth: 59 (25) | Birth weight > 4000 gm: 60 (25) | Percentile weight > 90: 60 (25) | Percentile weight < 10: 12 (6) | | NICU admission: 35 (15) | 3661 gm (sd: 629)
| | OR: 1.27 (95% CI: 0.84–1.94) | OR: 1.18 (95% CI: 0.75–1.85) | OR: 1.28 (95% CI: 0.82–2) | OR: 1.44 (95% CI: 0.91–2.27) | OR: 0.62 (95% CI: 0.26–1.43) | | OR: 0.57 (95% CI: 0.34–0.93) | p = 0.28*
| | | | | | | | birth trauma, claims data/ICD-9 codes total birth injuries: 8 (3)
| | | | | | | | congenital malformation, claims data/ICD-9 codes: 4 (2)
Conway, 2004^47^ | G1: glyburide failure, 12 | | | Birth weight > 4000 gm: 1 (8) | | | | | 3327 gm (sd: 634)
| G2: glyburide success, 63 | | | Birth weight > 4000 gm: 7 (11) | | | | | 3267 gm (sd: 815)
| | | | p = 1.0* | | | | | p = 0.78*
Chmait, 2004^45^ | G1: glyburide failure (glyburide + diet + insulin OR insulin + diet), 13 | Fsg < 40 mg/dL: 0 (0.00) | Serum bilirubin > 15 mg/dL: 1 (8.33) | Birth weight > 4000 gm: 2 (10) | | | Fetal mortality: 0 (0) | NICU admission: 1 (8) | 3608 gm (sd: 398)
| G2: glyburide success (glyburide + diet), 56 | Fsg < 40 mg/dL: 1 (1.85) | Serum bilirubin > 15 mg/dL: 2 (3.70) | Birth weight > 4000 gm: 15 (18) | | | Fetal mortality: 1 (2) | NICU admission: 4 (7) | 3430 gm (sd: 714)
| | | | p > 0.05* | | | p > 0.05* | p > 0.05* | p > 0.05*
Rochon, 2006^49^ | G1: Glyburide failure (NPH and regular insulin), 21 | Any heel stick ≤ 40 mg/dL: 2 (10) | Requiring NICU admission: 0 (0) | Birth weight > 4000 gm: 2 (11) | | | | NICU admission: 2 (10) | 3319 gm (sd: 559)
| | | | | | | | OR: ref
| | | | | | | | shoulder dystocia: 2 (11)
| G2: Glyburide success (glyburide + diet), 80 | Any heel stick ≤ 40 mg/dL: 10 (13) | Requiring NICU admission: 2 (3) | Birth weight > 4000 gm: 13 (16) | | | | NICU admission: 26 (33) | 3415 gm (sd: 620)
| | | | p = 0.445^*^ | | | | p = 0.037 | P = 0.518
| | | | | | | | OR: 4.57 (95% CI: 3.04–6.10)
| | | | | | | | shoulder dystocia: 7 (10)
| | | | | | | | p = 0.932

* Comparing G1 to G2

th CI = confidence interval; dL = deciliter; fsg = fingerstick glucose; G = group; gm = gram; ICD-9-CM = International Classification of Diseases - 9 revision - Clinical Modification; LGA = large for gestational age; mg = milligrams; NICU = neonatal intensive care unit; OR = odds ratio; ref = reference group; sd = standard deviation; SGA = small for gestational age

Evidence Table 9. Quality of studies reporting on the effects of oral hypoglycemic agents or insulin on maternal and neonatal outcomes: nonrandomized controlled trials and observational studies

Author, year | Are pre-specified hypotheses stated? | Are inclusion and exclusion criteria reported? | Sampling | Were power or sample size calculations used? | Does the article state how the outcome was defined? | Loss to followup / Loss to followup described | Missing data / described how missing data handled
Jacobson, 2005^48^ | | • | Consecutive | | •
Yogev, 2004^46^ | | • | Consecutive | | • | <10% / NA | <10% / NA
Chmait, 2004^45^ | • | • | Consecutive | | • | <10% / • | <10% / •
Conway, 2004^47^ | • | • | Consecutive | | • | <10% / | / •
Rochon, 2006^49^ | | • | Consecutive | | • | <10% /

• = Yes;

blank space = No/Not reported

NA = not applicable

Evidence Table 10. Characteristics of studies reporting on the effects of labor management on maternal and neonatal outcomes

Author, year | Time period | OGTT | Mean age (in years), (Age range) | Race, n (%) | Gravida and parity, mean | Intervention/Exposure, N
Country | | GA at diagnosis (in weeks)
Study design
Kjos, 1993^55^ | Start year: 1987 | 100-gm O'sullivan or NDDG | C: 31.9 (30.8–33.0) | C: NR | C: Gravidity: 4.1 | C: Induced if EFW ≥ 4200 gm or 42 weeks, 100
US | End year: 1991 | C: 38 weeks, 2 days | | | Parity: 2.4
RCT
| | I: 38 weeks, 1 day | I: 32.1 (30.9–33.2) | I: NR | I: Gravidity: 4.3 Parity: 2.5 | I: Induced at 38 weeks, 100
Conway, 1998^53^ | Start year: 1990 | 100-gm O'sullivan or NDDG | HC: NR | HC: Hisp: (84.7) | HC: NR | HC: Expectant management, 1227
US | End year: 1995 | HC: NR | | Cauc: (12.1)
Cohort | | | | AA: (3.2)
| | E: NR | E: NR | E: Hisp: (86.4) | E: NR | E: Ultrasound at 37–38 weeks; CD if EFW > 4250 gm, induced if LGA and EFW < 4250 gm, 1337
| | | | Cauc: (9.9)
| | | | AA: (3.7)
Lurie, 1996^58^ | Start year: 1983 | 100-gm O'sullivan or NDDG | HC: 33.1 | HC: NR | HC: Parity: 2.5 | HC: Induced if EFW > 4000 gm
Israel | End year: 1994 | HC: NR | | | | CD if EFW > 4500 gm, 164
Cohort | | E: NR | E: 32.5 | E: NR | E: Parity: 1.9 | E: Induced at 38 weeks, CD if EFW > 4500 gm, 96
Lurie, 1992^57^ | Start year: 1983 | 100-gm O'sullivan or NDDG | NR for any group | NR for any group | NR for any group | GDMA1:
Israel | End year: 1988 | NR for any group | | | | > 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 65
Cohort | | | | | | < 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 65
| | | | | | GDMA2:
| | | | | | > 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 59
| | | | | | < 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 59
Peled, 2004^59^ | Start year: 1980 | 100-gm Carpenter and Coustan criteria 100-gm O'sullivan or NDDG | NR for any group | NR for any group | NR for any group | Period A: Induced at 42 weeks, CD if EFW > 4500 gm, 878
Israel | End year: 1999 | 75-gm ADA | | | | Period B: Induced at 40 weeks if LGA, CD if EFW > 4000 gm, 347
Cohort | | NR for any group | | | | Period C: Induced at 40 weeks if LGA, CD if EFW > 4000 gm, 317
| | | | | | Period D: Induced at 38 weeks if LGA, CD if EFW > 4000 gm, 518
Rayburn, 2005^56^ | Start year: 2000 | 100-gm, 3-hr OGTT, ACOG | C: 30 | C: AA: (1) | C: (0, %: 31; 1, %: 20; >=2, %: 49) | C: GDMA1, expectant management, 137
US | End year: 2004 | C: NR | | Cauc: (15)
Cohort | Planned study period: 49 months | | | Hisp: (60)
| | | | Am. Ind: (20)
| | | | Other: (4)
| | E: NR | E: 30 | E: AA: (0) | E: (0, %: 18; 1, %: 33; >=2, %: 49) | E: GDMA2, Induced at 38 weeks, 143
| | | | Cauc: (17)
| | | | Hisp: (70)
| | | | Am. Ind: (6)
| | | | Other: (7)
Marchiano, 2004^52^ | Start year: 1995 | 100-gm O'sullivan or NDDG | C: 31.1 | C: AA: (25) | C: Gravida: 3.4 | C: Trial of labor after CD, 423
US | End year: 1999 | C: 38.3 | | Cauc: (57)
Cohort | | | | Asian: (3)
| | | | Hisp: (11)
| | | | Other: (4)
| | E: 38 | E: 32.2 | E: AA: (20) | E: Gravida: 3.1 | E: Repeat elective cesarean, 440
| | | | C: (64)
| | | | Asian: (3)
| | | | Hisp: (9)
| | | | Other: (5)
Keller, 1991^54^ | Start year: 1983 | 100-gm O'sullivan or NDDG | NR for any group | NR for any group | NR for any group | C: Trial of labor, 173
US | End year: 1989
Cohort | Planned study period: 70 months

AA = African American; ACOG = American College of Obstetrics and Gynecologists; ADA = American Diabetes Association; Asian = Asian or Asian American; C = control group; Cauc = Caucasian; CD = cesarean delivery; E = exposure group; EFW = estimated fetal weight; GA = gestational age; GDMA1 = diet-controlled; GDMA2 = requiring medical therapy; gm = gram; HC = historical control group; Hisp = Hispanic; I = intervention group; LGA = large for gestational age; NDDG = National Diabetes Data Group; NR = not reported; OGTT = oral glucose tolerance test; RCT = randomized controlled trial; US = United States

Evidence Table 11. Effects of labor management on maternal outcomes

Author, year | Level of analysis | Intervention/Exposure, N | GA at delivery (in weeks), mean (SD) | GA determined by | Operative vaginal delivery, n (%) | Cesarean delivery, n (%)
Kjos, 1993^55^ | Intervention | C: Induced if EFW ≥ 4200 gm or 42 weeks, 100 | 40 | LMP; 1st trimester ultrasound | | 31 (31)
| | I: Induced at 38 weeks, 100 | 39 | LMP; 1st trimester ultrasound; amniocentesis if indicated | | 25 (25)
| | | | | | p = 0.43
Conway, 1998^53^ | Protocol-based | HC: Expectant management, 1227 | 39.3 (1.5) | NR | | 266 (21.7)
| | E: Ultrasound at 37–38 weeks; CD if EFW > 4250 gm, induced if LGA and EFW < 4250 gm, 1337 | 39.2 (1.6) | NR | | 343 (25)
| | | | | | p < 0.04
Lurie, 1996^58^ | Protocol-based | HC: Induced if EFW > 4000 gm | 39.2 | LMP; 1st trimester ultrasound | Vacuum: 9 (6) | 31 (19)
| | CD if EFW > 4500 gm, 164
| | E: Induced at 38 weeks, CD if EFW > 4500 gm, 96 | 38.4 | LMP 1st trimester ultrasound; amniocentesis to confirm fetal lung maturity | Vacuum: 5 (5) | 22 (23)
| | | | | p: NS | p: NS
Lurie, 1992^57^ | Protocol-based | GDMA1: | 40.9 | LMP; 1st trimester ultrasound | Vacuum: 4 (6) | 9 (14)
| | > 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 65
| | < 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 65 | 38.2 | LMP; 1st trimester ultrasound | Vacuum: 0 (0) | 7 (11)
| | | | | p = 0.0997^†^ | p = 0.0997^†^
| | > 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 59 | 40.5 | LMP; 1st trimester ultrasound | Vacuum: 4 (7) | 13 (22)
| | GDMA2: | 37.5 | LMP; 1st trimester ultrasound | Vacuum: 1 (2) | 15 (25)
| | < 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 59 | | | p = 0.6216^†^ | p = 0.6216^†^
Peled, 2004^59^ | Protocol-based | Period A: Induced at 42 weeks, CD if EFW > 4500 gm, 878 | 39 (2.5) | LMP; +/- 1st trimester ultrasound | | 184 (21)
| | Period B: Induced at 40 weeks if LGA, CD if EFW > 4000 gm, 347 | 39 (1.5) | LMP; +/- 1st trimester ultrasound | | 62 (18)
| | Period C: Induced at 40 weeks if LGA, CD if EFW > 4000 gm, 317 | 38 (1.6) | LMP; +/- 1st trimester ultrasound | | 51 (16)
| | Period D: Induced at 38 weeks if LGA, CD if EFW > 4000 gm, 518 | 38.1 (3.1) | LMP; +/- 1st trimester ultrasound | | 176 (34)
Additional studies
Rayburn, 2005^56^ | Exposure | C: GDMA1, Expectant management, 137 | 39 (1) | 1st trimester ultrasound; amniocentesis if needed | | 16 (12)
| | E: GDMA2, Induced at 38 weeks, 143 | 38.1 (0.3) | 1st trimester ultrasound; amniocentesis if needed | | 19 (13)
| | | | | | p = 0.8
Marchiano, 2004^52^ | exposure | C: Trial of labor after CD, 423 | 38.3 (2.2) | NR | | Failed VBAC: 128 (30)*
| | E: Repeat elective cesarean, 440 | NR | NR | | NA
Keller, 1991^54^ | exposure | C: Trial of labor, 173 | NR | NR | Forceps: 8 | 53 (30.6)

* The birth weight was greater than or equal to 4000 gm for 32 (25%) and less than 4000 gm for 96 (75%) of the infants of the 128 women who failed the VBAC attempt.

† Comparing > 40 weeks to < 40 weeks for all modes of delivery

C = control group; CD = cesarean delivery; E = exposure group; EFW = estimated fetal weight; GDMA1 = diet-controlled; GDMA2 = requiring medical therapy; gm = gram; HC = historical control group; I = intervention group; LGA = large for gestational age; LMP = last menstrual period; NR = not reported; NS = not significant; SD = standard deviation; VBAC = vaginal birth after cesarean

Evidence Table 12. Effects of labor management on neonatal outcomes

Author, year | Level of analysis | Intervention/Exposure, N | GA at delivery (in weeks), mean (SD) | GA determined by | Macrosomia or LGA (PW>90%), n (%) | Birth weight (in grams), mean | Shoulder dystocia, n (%) | Birth trauma, n (%) | Mortality, n (%) | Other outcome, n (%)
Kjos, 1993^55^ | Intervention | C: Induced if EFW ≥ 4200 gm or 42 weeks, 100 | 40 | LMP; 1st trimester ultrasound | Birth weight > 4000 gm: 27 (27) | 3672 (95% CI: 3595 – 3749) | 3 (3.00) | Bone fracture, nerve palsy: 0 (0) | Perinatal/neonatal mortality: 0 (0) | Hypoglycemia: 0 (0)
| | | | | > 4500 gm: 2 (2) | | | | | Congenital malformation: 0 (0)
| | | | | LGA: 23 (23)
| | I: Induced at 38 weeks, 100 | 39 | LMP; 1st trimester ultrasound; amniocentesis if indicated | Birth weight > 4000 gm: 15 (15) | 3446 (95% CI: 3368 – 3522) | 0 (0) | Bone fracture, nerve palsy: 0 (0) | Perinatal/neonatal mortality: 0 (0) | Hypoglycemia: 0 (0)
| | | | | p = 0.05* | p < 0.0001* | | | | Congenital malformation: 0 (0)
| | | | | > 4500 gm: 0 (0)
| | | | | LGA: 10 (10)
| | | | | p = 0.02*
Conway, 1998 ^53^ | Protocol-based | HC: Expectant management, 1227 | 39.3 (1.5) | NR | Birth weight > 4000 gm: 147 (12) | | (2.8) | Bone fracture, nerve palsy: 12 (41)
| | | | | LGA: 233 (19) | | OR: 1.9 (95% CI: 1 – 3.5)
| | E: Ultrasound at 37–38 weeks; CD if EFW > 4250 gm, induced if LGA and EFW < 4250 gm, 1337 | 39.2 (1.6) | NR | Birth weight > 4000 gm: 120 (9) | | (1.5) | Bone fracture, nerve palsy: 7 (47)
| | | | | p = 0.04^†^
| | | | | LGA: 227 (17)
| | | | | p: NS^†^
Lurie, 1996^58^ | Protocol-based | HC: Induced if EFW > 4000 gm; CD if EFW > 4500 gm, 164 | 39.2 | LMP; 1st trimester ultrasound | Birth weight > 4000 gm: 30 (18) | 3430.1 (530.0) | 7 (5) | Clavicle fracture, nerve palsy: 3 (1.83) | Perinatal/neonatal mortality: 0 (0.00) | RDS: 0 (0)
| | E: Induced at 38 weeks, CD if EFW > 4500 gm, 96 | 38.4 | LMP; 1st trimester ultrasound; amniocentesis for lung maturity | Birth weight > 4000 gm: 9 (9) | 3406.7 (493.4) | 1 (1) | Clavicle fracture, nerve palsy: 0 (0.00) | Perinatal/neonatal mortality: 1 (1.04) | RDS: 0 (0)
| | | | | p: NS^†^ | | p: NS^†^
Lurie, 1992 ^57^ | Protocol-based; divided into groups based on gestational age at delivery | GDMA1: | 40.9 | LMP; 1st trimester ultrasound | Birth weight > 4000 gm: 16 (25) | 3617.85 (sd: 485.12) | 2 (3.57) | Clavicle fracture, nerve palsy: 0 (0) | Perinatal/neonatal mortality: 0 (0) | Hypoglycemia: 2 (3)
| | > 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 65 | | | | | | | | RDS: 0 (0)
| | | | | | | | | | Hyperbilirubinemia: 2 (3)
| | < 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 65 | 38.2 | LMP; 1st trimester ultrasound | Birth weight > 4000 gm: 10 (15) | 3439.00 (sd: 584.21) | 0 (0.00) | Clavicle fracture, nerve palsy: 0 (0) | Perinatal/neonatal mortality: 0 (0) | Hypoglycemia: 2 (3)
| | | | | p = 0.1853^‡^ | p = 0.0619^‡^ | p = 0.5328^‡^ | | | p: NS^‡^
| | | | | | | | | | RDS: 0 (0)
| | | | | | | | | | Hyperbilirubinemia: 1 (2)
| | | | | | | | | | p: NS^‡^
| | GDMA2: | 40.5 | LMP; 1st trimester ultrasound | Birth weight > 4000 gm: 12 (20) | 3639.15 (sd: 491.84) | 1 (2.17), | Clavicle fracture, nerve palsy: 2 (4.35) | Perinatal/neonatal mortality: 0 (0) | Hypoglycemia: 5 (8)
| | > 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 59 | | | | | | | | RDS: 0 (0)
| | | | | | | | | | Hyperbilirubinemia: 3 (5)
| | < 40 weeks: Induced if EFW > 4000 gm, CD if EFW > 4500 gm, 59 | 37.5 | LMP; 1st trimester ultrasound | Birth weight > 4000 gm: 4 (7) | 3275.34 (sd: 570.15) | 2 (4.55) | Clavicle fracture, nerve palsy: 1 (2.27) | Perinatal/neonatal mortality: 0 (0) | Hypoglycemia: 6 (10)
| | | | | p = 0.0567^‡^ | p = 0.0003^‡^ | p = 0.9676^‡^ | | | p: NS^‡^
| | | | | | | | | | RDS: 0 (0)
| | | | | | | | | | Hyperbilirubinemia: 3 (5)
| | | | | | | | | | p: NS^‡^
Peled, 2004 ^59^ | protocol period | Period A: Induced at 42 weeks, CD if EFW > 4500 gm, 878 | 39 (2.5) | LMP; +/- 1st trimester ultrasound | Birth weight > 4000 gm: 167 (19) | | 18 (2) | | Perinatal/neonatal mortality: 70 (8)
| | Period B: Induced at 40 weeks if LGA, CD if EFW > 4000 gm, 347 | 39 (1.5) | LMP; +/- 1st trimester ultrasound | Birth weight > 4000 gm: 56 (16) | | 3 (1) | | Perinatal/neonatal mortality: 10 (3)
| | Period C: Induced at 40 weeks if LGA, CD if EFW > 4000 gm, 317 | 38 (1.6) | LMP; +/- 1st trimester ultrasound | Birth weight > 4000 gm: 38 (12) | | 3 (1) | | Perinatal/neonatal mortality: 0 (0)
| | Period D: Induced at 38 weeks if LGA, CD if EFW > 4000 gm, 518 | 38.1 (3.1) | LMP; +/- 1st trimester ultrasound | Birth weight > 4000 gm: 21 (4) | | 0 (0) | | Perinatal/neonatal mortality: 5 (1)
Additional studies
Rayburn, 2005^56^ | exposure | C: GDMA1, Expectant management, 137 | 39 (1) | 1st trimester ultrasound amniocentesis if needed | Birth weight > 4000 gm: 11 (8) | 3311 (sd: 489) | 3 (2) | clavicle fracture, nerve palsy: 0 (0.00) | Fetal mortality: 1 (1) | RDS: 0 (0.00)
| | E: GDMA2, Induced at 38 weeks, 143 | 38.1 (0.3) | 1st trimester ultrasound amniocentesis if needed | Birth weight > 4000 gm: 6 (4) | 3306 (sd: 396) | 6 (4) | clavicle fracture, nerve palsy: 0 (0.00) | Fetal mortality: 0 (0) | RDS: 0 (0.00)
| | | | | p = 0.18^¶^ | p = 0.93^¶^ | p = 0.77^¶^
Marchiano, 2004 ^52^ | exposure | C: Trial of labor after CD, 423 | 38.3 (2.2) | NR | Birth weight > 4000 gm: 76 (18)
| | E: Repeat elective cesarean, 440 | 38 (3.2) | NR | Birth weight > 4000 gm: 145 (33)
| | | | | p < 0.0001^¶^

* Comparing C to I.

† Comparing HC to E.

‡ Comparing >40 weeks to <40 weeks.

¶ Comparing C to E.

C = control group; CD = cesarean delivery; CI = confidence interval; E = exposure group; EFW = estimated fetal weight; GA = gestational age; GDMA1 = diet-controlled; GDMA2 = requiring medical therapy; gm = gram; HC = historical control group; I = intervention group; LGA = large for gestational age; LMP = last menstrual period; NR = not reported; NS = not significant; OR = odds ratio; PW = percentile weight; RDS = respiratory distress syndrome; SD = standard deviation

Evidence Table 13. Quality of studies reporting on the effects of labor management on maternal and neonatal outcomes

Author, year | Hypotheses stated | Inclusion criteria reported | Sampling | Power/Sample size calculations | Outcomes defined | Loss to followup/reported in analysis | Missing data/reported in analysis | Analysis adjusted
Conway, 1998^53^ | • | • | Consecutive | | • | <10%/ NA | <10%/ NA
Lurie, 1996^58^ | | • | Consecutive | • | • | <10% / NA | <10% / NA
Lurie, 1992^57^ | | • | Consecutive | | | <10% / NA | <10% / NA
Peled, 2004^59^ | | | Consecutive | | • | <10% / NA | <10% / NA
Rayburn, 2005^56^ | | • | Consecutive | • | | <10% / NA | <10% / NA | •
Marchiano, 2004^52^ | • | • | Consecutive | | • | <10% / NA | 10–20% / • | •
Keller, 1991^54^ | | • | Consecutive | | • | <10% / NA | <10% / NA

Evidence Table 13a. Quality of studies reporting on the effects of labor management on maternal and neonatal outcomes

Author, year | Randomized | Randomization scheme described | Double blinded | Blinding described | Withdrawals described | Quality score*
Kjos, 1993^55^ | • | | | | • | 2

• = Yes;

blank space = No/Not reported;

NA= not applicable

* Total quality score calculated using the Jadad^22^ criteria.

Evidence Table 14. Grading of the body of evidence of the effects of labor management on maternal and neonatal outcomes (KQ2)

| Labor management on maternal and neonatal outcomes
[underlined: Quantity of evidence:] | 8
Number of studies
Total number of patients studied | 6648
[underlined: Quality and consistency of evidence:] | Low
Were study designs mostly randomized trials (high quality), non-randomized controlled trials (medium quality), observational studies (low quality), or about a 50:50 mix of experimental and observational (medium quality)?
Did the studies have serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -2
Did the studies have important inconsistency? (-1) | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, interventions and outcomes are similar to those of interest)? | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1
Did the studies have high probability of reporting bias? (-1) | 0
Did the studies show strong evidence of association between intervention and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | +1
Overall grade of evidence (high, moderate, low, very low) | Very low

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research [underlined: is likely to] have an important impact on our confidence in the estimate of effect and is likely to change the estimate; very low = any estimate of effect is very uncertain.

Evidence Table 15. List of covariates considered and included in models assessing the association of risk factors with the development of type 2 diabetes following a pregnancy with gestational diabetes

Covariate | Buchanan, 1998^75^ | Buchanan, 1999^74^ | | | Cheung, 2006^60^ | | Cho, 2005^61^ | Cho, 2006^62^ | | | | | | | | Dacus, 1994^65^ | Jang, 2003^63^ | Kjos, 1995^68^
# abnormal OGTT results
# prior GDM pregnancies | | | | | ○ | •
% pre-pregnancy obesity
1-hr plasma glucose diagnostic OGTT | | ○ | • | •
2-hr glucose | | | | | | | | | | | | | | | | | •
2-hr OGTT | | | | | ○ | •
3-hr insulin on diagnostic OGTT | | | | | | | | | | | | | | | | | •
50-gm GCT
75-gm OGTT glucose AUC | ○
8-year DM risk (%)
Additional pregnancy
Age | ○ | ○ | ○ | ○ | ○ | • | • | • | • | • | • | • | • | • | • | ○ | • | ○
Antepartum 30 min incremental plasma insulin/glucose | •
Antepartum OGTT glucose AUC | | | | | | | | | | | | | | | | | | •
Antepartum plasma glucose 1-hr at screening | | ○ | ○ | ○
Area under the glucose curve or pregnancy OGTT
AUC at initial postpartum OGTT
Basal glucose production rate | | • | • | •
Beta-cell compensation index | | ○ | ○ | •
Blood pressure | | | | | | | | • | • | • | • | • | • | • | •
BMI
BMI at GTT
BMI at index pregnancy | | | | | ○ | •
Body fat % | | | | | | | | ○ | ○ | ○ | ○ | ○ | ○ | ○ | ○
Body fat weight | | | | | | | | ○ | ○ | ○ | • | ○ | ○ | ○ | ○
Breastfeeding | ○
Clamp SI | | • | • | ○
Class A2
Completion of 2^nd^ pregnancy
Contraceptive use
C-peptide glucose score
Dose of bedtime intermediate-acting insulin required | | | | | • | ○
Duration of followup | | | | | | | | • | • | • | • | • | • | • | •
Duration of OC use
Fasting blood glucose level | | | | | • | ○
Fasting blood sugar
FHxT2DM | | | | | ○ | • | • | • | • | ○ | • | • | • | • | • | | •
FPG at diagnosis | | | | | ○ | • | •
FSIGT acute insulin response | | ○ | ○ | ○
FU months
GAD and IA-2 antibody status
GDM class A1 | | | | | | | | | | | | | | | | | ○
Gestational age at delivery | ○ | ○ | ○ | ○ | | | | | | | | | | | | | ○
Gestational age at GDM diagnosis | | | | | | | • | | | | | | | | | ○ | • | •
GTT total
HDL cholesterol
Height | | | | | | | | | | | | | | | | | •
Highest antepartum fasting glucose | | | | | | | | | | | | | | | | | | •
Highest FPG | ○
HLA DR3 or DR4-DQ8
Homocysteine level | | | | | | | •
Hospital | | | | | ○ | •
Incremental glucose area, diagnostic OGTT | | • | ○ | ○
Insulin | | | | | | | | | | | | | | | | | •
Interaction term for breastfeeding and OC use
Interaction term of OC use and triglyceride level
Lipid profile which includes triglyceride, HDL and LDL and cholesterol | | | | | | | | • | • | • | • | • | • | • | •
Mean arterial pressure
Mean BMI at 1^st^ antenatal visit
Method of glucose control | ○ | | | | ○ | • | ○ | | | | | | | | | ○
OGTT 30-min incremental insulin: glucose | | • | • | ○
OGTT glucose area
Parity | | | | | ○ | • | ○ | • | • | • | • | • | • | • | • | | ○ | ○
Postpartum BMI | ○ | ○ | ○ | ○ | | | | ○ | ○ | ○ | ○ | • | ○ | ○ | ○ | ○ | | ○
Postpartum FPG
Postpartum OGTT glucose AUC | | | | | | | | | | | | | | | | | | •
Postpartum weight | | | | | | | | | | | | | | | | | •
Postpartum weight change | | ○ | ○ | ○ | | | | ○ | ○ | ○ | ○ | ○ | ○ | • | ○
Pregnancy weight gain | ○ | ○ | ○ | ○
Pre-pregnancy BMI | ○ | ○ | ○ | ○ | | | • | | | | | | | | | | •
Pre-pregnancy weight | | | | | | | | | | | | | | | | | •
Previous macrosomia
Previous stillbirth
Prior OC use
Race | ○ | ○ | ○ | ○ | | | | | | | | | | | | ○ | | ○
Serum CRP
Spontaneous abortions
Subscapular skin fold thickness | | | | | | | | ○ | ○ | ○ | ○ | ○ | • | ○ | ○
Suprailiac skin fold thickness | | | | | | | | • | ○ | ○ | ○ | ○ | ○ | ○ | ○
Total AUC for diagnostic antepartum 100-gm OGTT glucose | •
Total cholesterol | | | | | | | | ○ | ○ | ○ | ○ | ○ | ○ | ○ | ○
Triceps skin fold thickness | | | | | | | | ○ | • | ○ | ○ | ○ | ○ | ○ | ○
Triglycerides | | | | | | | | ○ | ○ | ○ | ○ | ○ | ○ | ○ | ○
Waist circumference | | | | | | | | ○ | ○ | ○ | ○ | ○ | ○ | ○ | •
Wait-to-hip ratio | | | | | | | | ○ | ○ | • | ○ | ○ | ○ | ○ | ○
Working status | | | | | | | | • | • | ○ | • | • | • | • | •

Evidence Table 15. List of covariates considered and included in models assessing the association of risk factors with the development of type 2 diabetes following a pregnancy with gestational diabetes

Covariate | Kjos, 1998^69^ | Lobner, 2006^66^ | Pallardo, 1999^73^ | Peters, 1996^72^ | Schaefer-Graf, 2002^70^ | Steinhart, 1997^71^ | Xiang, 2006^64^ | | | Metzger, 1993^67^
# abnormal OGTT results | | | •
# prior GDM pregnancies | | | ○ | | • | ○
% pre-pregnancy obesity | | | ○
1-h plasma glucose diagnostic OGTT
2-hr glucose | | | | | | | | | | ○ | •
2-hr OGTT
3-hr insulin on diagnostic OGTT
3-hr integrated insulin | | | | | | | | | | • | ○
50-gm GCT | | | | | •
75-gm OGTT glucose AUC
8-year DM risk (%) | | ○
Additional pregnancy | ○ | | | •
Age | ○ | • | ○ | ○ | ○ | ○ | ○ | ○ | ○ | ○ | ○
Antepartum 30 min incremental plasma insulin/glucose
Antepartum OGTT glucose AUC
Antepartum plasma glucose 1-hr at screening
Area under the glucose curve of pregnancy OGTT | | | | | •
AUC at initial postpartum OGTT | •
Basal glucose production rate | | | | | | | | | | ○ | ○
Basal Insulin | | | | | | | | | | ○ | •
Beta-cell compensation index
Blood pressure
BMI | | ○
BMI at GTT | | | | | | ○
BMI at index pregnancy
Body fat %
Body fat weight
Breastfeeding | | | | • | | | • | • | ○
Clamp S1
Class A2 | | | | | •
Completion of 2^nd^ pregnancy | •
Contraceptive use | • | | | ○ | | | • | ○ | ○
C-peptide glucose score | | | •
Diagnostic OGTT
Dose of bedtime intermediate-acting insulin required
Duration of followup | | | | ○
Duration of OC use | •
Fasting blood glucose level
Fasting blood sugar | | | | | | ○
FHxT2DM | | | ○ | | | | • | • | • | ○ | ○
FPG at diagnosis | | | | | •
FSIGT acute insulin response
FU months
GAD and IA-2 antibody status | | •
GDM class A1
GDM recurrence | | | ○ | | | ○
Gestational age at delivery | | | | ○
Gestational age at GDM diagnosis | | | | | •
GTT total | | | | | | ○
HDL cholesterol | | | | | | | • | • | ○
Height
Highest antepartum fasting glucose
Highest FPG
HLA DR3 or DR4-DQ8 | | ○
Homocysteine level
Hospital
Incremental glucose area
Insulin
Interaction term for breastfeeding and OC use | | | | | | | ○ | ○ | •
Interaction term of OC use and triglyceride level | | | | | | | ○ | • | ○
Lipid profile which includes triglyceride, HDL and LDL and cholesterol
Mean arterial pressure | ○
Mean BMI at 1^st^ antenatal visit
Method of glucose control | • | • | | | | ○ | ○ | ○ | ○
Obesity | | | | | | | | | | • | ○
OGTT 30-min incremental insulin: glucose
OGTT 30-min stimulated insulin secretion | | | | | | | | | | ○ | •
OGTT glucose area | | | | •
Parity | ○ | • | ○ | ○ | ○ | ○ | ○ | ○ | ○ | • | ○
Postpartum BMI | ○ | | | • | | | • | • | •
Postpartum FPG | ○
Postpartum OGTT glucose AUC
Postpartum weight
Postpartum weight change | • | | | • | | | • | • | •
Pregnancy weight gain
Pre-pregnancy BMI | | | ○
Pre-pregnancy weight
Previous GDM | | | | | ○
Previous macrosomia | | | | | ○
Previous stillbirth | | | | | ○
Prior OC use | •
Race | ○ | | ○ | ○ | | ○ | ○ | ○ | ○ | ○ | ○
Serum CRP | | ○
Spontaneous abortions | | | | | | ○
Subscapular skin fold thickness
Suprailiac skin fold thickness
Total AUC for diagnostic antepartum 100-gm OGTT glucose
Total cholesterol | ○
Triceps skin fold thickness
Triglycerides | | | | | | | • | ○ | •
Waist circumference
Wait-to-hip ratio
Working status

○ = Variable considered in multivariate model;

• = variable included in multivariate model

AUC = area under the curve; BMI = body mass index; CRP= C-reactive protein; DM = diabetes mellitus; FH = family history; FPG = fasting plasma glucose; FSIGT = frequently sampled intravenous glucose tolerance; FU = followup; GAD = glutamic acid decarboxylase; GCT = glucose challenge test; GDM = Gestational diabetes mellitus; gm = gram; GTT = glucose tolerance test; HDL = high density lipoprotein; HLA = human leukocyte antigen; hr = hour; IA-2 = Insulinoma antigen-2; LDL = low density lipoprotein; min = minute; OC = oral contraceptive; OGTT = oral glucose tolerance test; T2DM = Type 2 diabetes mellitus.

Evidence Table 16. Characteristics of studies reporting on the risk associated with the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Age (in years), mean | Race, n (%) | Gravida and parity, mean | N | Diabetes diagnosis | Followup time | Covariates considered
Country
Study design
Buchanan, 1998^75^ | NGT: 30.8 | NGT: Hisp: 49 (100) | NR | 122 | Abnormal 75-gm OGTT | 0–6 months | Age, race, pregnancy weight gain, pre-pregnancy BMI, postpartum BMI, gestational age at delivery, method of glucose control, 75-gm OGTT glucose AUC, breastfeeding, highest FPG, antepartum 30 minutes incremental plasma insulin/glucose, total AUC for diagnostic antepartum 100-gm OGTT glucose
US | IGT: 29.3 | IGT: Hisp: 61 (100)
Cohort | T2DM: 32.3 | T2DM: Hisp: 12 (100)
Buchanan, 1999^74^ | ND: 30.3 | ND: Hisp: 77 (100) | NR | 91 | Abnormal 75-gm OGTT | 11–26 months | Age, race, pregnancy weight gain, pre-pregnancy BMI, postpartum BMI, gestational age at delivery, antepartum plasma glucose (1-hr) at screening, incremental glucose area, diagnostic OGTT, postpartum weight change, 1-hr plasma glucose diagnostic OGTT, beta-cell compensation index, basal glucose production rate, OGTT 30-min incremental insulin:glucose, clamp SI, FSIGT acute insulin response
US | T2DM: 29.6 | T2DM: Hisp: 14 (100)
Cohort
Cheung, 2006^60^ | ND: 32.3 | NR | ND: parity: 1.6 | 102 | Abnormal 75-gm OGTT, self report followed by verification from local doctor or abnormal 75-gm OGTT at retest | 0–8 years, mean=4.5 years | Age, parity, FPG at diagnosis, BMI at index pregnancy, 2-hr OGTT, # prior GDM pregnancies, method of glucose control, FHxT2DM, hospital, fasting blood glucose level, dose of bedtime intermediate-acting insulin required
Australia | T2DM: 31.9 | | T2DM: parity: 0.9
Cohort | T: 32.1 | | T: parity: 1.4
Cho, 2005^61^ | NGT: 30.6 | NR | NGT: (≥ 3 children (%): 32.1) | 170 | Abnormal 75-gm OGTT | 6 weeks and annually thereafter | Age, pre-pregnancy BMI, parity, method of glucose control, gestational age at GDM diagnosis, FHxT2DM, FPG at diagnosis, homocysteine level
Korea | IGT: 32.1 | | IGT: (≥ 3 children (%): 55.8)
Cohort | T2DM: 30 | | T2DM: (≥ 3 children (%): 33.3)
Cho, 2006^62^ | NGT: 33.2 | NR | NGT: | 909 | Abnormal 75-gm OGTT | 6 weeks, annually up to 6 years | Age, parity, body fat %, total cholesterol, triglycerides, postpartum BMI, blood pressure, lipid profile,* duration of followup, FHxT2DM, working status, postpartum waist circumference, postpartum weight, postpartum subscapular skin fold thickness, postpartum suprailiac skin fold thickness, postpartum tricep skin fold thickness, postpartum body fat weight, postpartum waist-to-hip ratio
Korea | | | (para 1 (%): 39.0; para 2 (%): 51.4; para 3+ (%): 9.5)
Cohort | IGT: 34.2 | | IGT:
| | | (para 1 (%): 37.8; para 2 (%): 56.9; para 3+ (%): 3.4)
| T2DM: 33 | | T2DM:
| | | (para 1 (%): 39.7; para 2 (%): 56.9; para 3+ (%): 3.4)
Dacus, 1994^65^ | ND: ≥30 year (n, %): 40 (47%); <30 year (n, %): 46 (53%) | ND: AA: 60 (70); | NR | 100 | Abnormal 75-gm OGTT | 5–10 weeks postpartum | Age, race, gestational age at GDM diagnosis, method of glucose control, postpartum BMI
US | | C: 23 (27);
Cohort | | Other: 3 (3)
| T2DM: ≥30 year (n, %): 5 (36%); <30 year (n, %): 9 (64%) | T2DM: AA: 11 (72); C: 2 (21);
| | Other: 1 (7)
Jang, 2003^63^ | T: 30.9 | T: NR | T: parity: 0.5 | 311 | Abnormal 75-gm OGTT | NR | Age, pre-pregnancy weight, pre-pregnancy BMI, parity, gestational age at delivery, GDM class A1, gestational age at GDM diagnosis, 2-hr glucose, 3-hr insulin on diagnostic OGTT, height, FHxT2DM, postpartum weight
Korea
Cohort
Kjos, 1995^68^ | T: 30.3 | T: Hisp: 671 (100) | T: parity: 2.8 | 671 | Abnormal 75-gm OGTT | Between 4 to 16 weeks; Additional followup within 7.5 years postpartum | Age, race, postpartum BMI, parity, postpartum OGTT glucose AUC, gestational age at GDM diagnosis, antepartum OGTT glucose AUC, highest antepartum fasting glucose
US
Cohort
Kjos, 1998^69^ | COC: 28.5 | COC: Hisp: 383 (100) | COC: parity: 2.3 | 443 | Abnormal 75-gm OGTT | Varied (Cox model) | Age, race, postpartum BMI, parity, method of glucose control, total cholesterol, mean arterial pressure, postpartum FPG, contraceptive use, AUC at the initial postpartum OGTT, prior OC use, additional pregnancy, postpartum weight change, duration of OC use
US | Progestin only: 29.4 | Progestin only: Hisp: 78 (100) | Progestin only: parity: 3.1
Cohort
Lobner, 2006^66^ | Autoantibody (+): 29.9 | NR | NR | 302 | Abnormal 75-gm OGTT | 9 months and 2, 5, 8 and 11 years postpartum | Age, BMI at first pregnancy visit, method of glucose control, HLA DR3 or DR4-DQ8, 8-year DM risk (%), GAD and IA-2 antibody status, parity, serum CRP
Germany | Autoantibody (-): 31.4
Cohort | T: NR
Metzger, 1993^67^ | Model 1 | NR | Model 1: parity | Model 1 | Abnormal 100-gm OGTT | 3–6 months (model 1), and year 1,2,3,4,&5 (model 2) | Age, race, FHxT2DM, parity, obesity, basal glucose, basal insulin, 2-hr glucose, 3-hr integrated insulin, OGTT 30-min stimulated insulin secretion
US | ND: 31.7 | | ND: 1.5 | 177
Cohort | IGT: 32.0 | | IGT: 1.5
| T2DM: 33.0 | | T2DM: 1.7
| Model 2 | | Model 2: parity | Model 2
| ND: 31.4 | | ND: 1.6 | 172
| IGT: 31.7 | | IGT: 1.3
| T2DM: 32.3 | | T2DM: 2.1
Pallardo, 1999^73^ | ND: 33.1 | ND: C: 745 (100) | ND: parity: 1.89 | 788 | Abnormal 75-gm OGTT | 3–6 months | Age, race, parity, pre-pregnancy BMI, recurrence of GDM, FHxT2DM, # of abnormal OGTT results (including fasting), C-peptide glucose score
Spain | T2DM: 32.6 | T2DM: C: 43 (100) | T2DM: parity: 1.94
Cohort
Peters, 1996^72^ | No additional pregnancy: 30.4 | No additional pregnancy: Hisp: 578 (100) | No additional pregnancy: parity: 2.8 | 666 | Abnormal 75-gm OGTT | 3–89 months | Age, race, parity, gestational age at delivery, duration of followup, oral contraceptive use, additional pregnancy, postpartum weight change, OGTT glucose area, postpartum BMI, breastfeeding
US | Additional pregnancy: 29.9 | Additional pregnancy: Hisp: 87 (100) | Additional pregnancy: parity: 2.8
Cohort
Schaefer-Graf, 2002^70^ | ND: 31.1 | NR | ND: parity: 1.9 | 1636 | Abnormal 75-gm OGTT, taking diabetes medications | 1–4 months | Age, parity, previous macrosomia, previous stillbirth, FPG at diagnosis, class A2, area under the glucose curve of pregnancy OGTT, gestational age at GDM diagnosis, previous GDM, 50-gm GCT
US | T2DM: 32.2 | | T2DM: parity: 2.2
Cohort | T: 31.2 | | T: NR
Steinhart, 1997^71^ | ND: 31 | ND: American Indian: 41 | ND: parity: 2.45 | 88 | Abnormal 75-gm OGTT, type 2 diabetes diagnosed in medical record | 9–12 years | Age, race, parity, BMI at GTT, fasting blood sugar, spontaneous abortions, GTT total, recurrent GDM, method of glucose control
US | NIDDM: 32.7 | NIDDM: American Indian: 47 | NIDDM: parity: 3.43
Cohort
Xiang, 2006^64^ | DMPA: 30 | DMPA: Hisp: 96 (100) | DMPA: parity: 2.6 | 526 | Abnormal 75-gm OGTT | 4–6 weeks, 3–6 month intervals thereafter | Age, race, parity, method of glucose control, contraceptive use, postpartum BMI, breastfeeding, FHxT2DM, HDL cholesterol, triglycerides, weight change during followup, interaction term for OC use and triglyceride level, interaction term for breastfeeding and OC use
US | COC: 29 | COC: Hisp: 430 (100) | COC: parity: 2.3
Cohort

* Includes triglyceride, high density lipoprotein, and low density lipoprotein cholesterol

AA = African American; AUC = area under the curve; BMI = body mass index; C = Caucasian; COC = combination oral contraceptive; CRP = C-reactive protein; DMPA = depomedroxyprogesterone acetate; FPG = fasting plasma glucose; FSIGT = frequently sampled intravenous glucose tolerance; GAD = glutamic acid decarboxylase; GCT = glucose challenge test; GDM = gestational diabetes mellitus; gm = gram; GTT = glucose tolerance test; HDL = high density lipoprotein; Hisp = Hispanic; HLA = human leukocyte antigen; hr = hour; IA-2 = insulinoma antigen-2; IGT = impaired glucose tolerance; min = minutes; ND = non-diabetic; NGT = normal glucose tolerance; NIDDM = non-insulin dependent diabetes mellitus; NR = not reported; OC = oral contraceptive; OGTT = oral glucose tolerance test; SI = sensitivity index; T2DM = type 2 diabetes mellitus; T = total; US = United States

Evidence Table 17. Quality of studies reporting on the risk associated with the development of type 2 diabetes following a pregnancy with gestational diabetes

Author, year | Are pre-specified hypotheses stated? | Are inclusion and exclusion criteria reported? | Sampling | Were power or sample size calculations used? | Does the article state how the outcome was defined? | Loss to followup / Report comparisons of those lost to followup vs participants | Percent of missing data / Report how missing data was handled
Buchanan, 1998^75^ | | • | Consecutive | | • | 10–20% / •
Buchanan, 1999^74^ | • | • | Convenience | | • | 10–20% /
Cheung, 2006^60^ | • | • | Convenience | | • | >20% / •
Cho, 2005^61^ | | • | Convenience | | • | >20% /
Cho, 2006^62^ | | • | Convenience | | • | >20% /
Dacus, 1994^65^ | • | • | Convenience | | • | >20% /
Jang, 2003^63^ | • | • | Convenience | | • | 10–20% / •
Kjos, 1995^68^ | • | • | Convenience | | • | >20% /
Kjos, 1998^69^ | | • | Consecutive | | •
Lobner, 2006^66^ | • | • | Convenience | | • | >20% /
Pallardo, 1999^73^ | • | • | Convenience | | • | >20% / •
Peters, 1996^72^ | | • | Consecutive | | •
Schaefer-Graf, 2002^70^ | • | • | Convenience | | • | >20% / • | 10–20% /
Steinhart, 1997^71^ | | • | Consecutive | | • | >20% /
Xiang, 2006^64^ | | • | Convenience

•=yes;

blank space=no/not reported

Evidence Table 18. Studies reporting on the association between a family history of type 2 diabetes mellitus and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Cheung, 2006^60^ | FHxT2DM | NR | 102 | Yes/no | Age, parity, FPG at diagnosis, BMI at index pregnancy, 2-hr OGTT, # prior GDM pregnancies, method of glucose control, hospital
Cho, 2005^61^ | FHxT2DM | Yes/no | 170 | No: ref | Age, gestational age at GDM diagnosis, pre-pregnancy BMI, FPG at diagnosis, homocysteine level
| | | | Yes: RR = 1.706 (0.638 – 4.566)
Cho, 2006^62^ | FHxT2DM | NR | 909 | NR | Cho reported 8 models, which adjusted for blood pressure, lipid profile*, age, duration of followup, parity, working status, and one of the following measures of adiposity at postpartum: BMI, waist circumference, weight, subscapular skin fold thickness, suprailiac skin fold thickness, tricep skin fold thickness, body fat weight, and waist-to-hip ratio. The relative measure for FHxT2DM was not reported in any of the models.
Jang, 2003^63^ | FHxT2DM | Yes/no | 311 | NR | Pre-pregnancy weight, gestational age at GDM diagnosis, 2-hr glucose, 3-hr insulin on diagnostic OGTT, age, height, pre-pregnancy BMI, postpartum weight
Xiang, 2006^64^ | FHxT2DM | Yes/no | 526 | NR | Contraceptive use, postpartum BMI, breastfeeding, HDL cholesterol, triglycerides, postpartum weight change
Xiang, 2006^64^ | FHxT2DM | Yes/no | 526 | NR | Interaction term for breastfeeding and OC use, postpartum BMI, triglycerides, HDL cholesterol, postpartum weight change
Xiang, 2006^64^ | FHxT2DM | Yes/no | 526 | NR | Interaction term for OC use and triglyceride level, postpartum BMI, breastfeeding, HDL cholesterol, postpartum weight change

* Includes triglyceride, high density lipoprotein, and low density lipoprotein cholesterol

BMI = body mass index; CI = confidence interval; FHxT2DM = family history of type 2 diabetes mellitus; FPG = fasting plasma glucose; GDM = gestational diabetes mellitus; HDL = high density lipoprotein; hr = hour; NR = not reported; OC = oral contraceptive; OGTT = oral glucose tolerance test; ref = reference group; RR = relative risk

Evidence Table 19. Studies reporting on the association between sociodemographics and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Cho, 2005^61^ | Age | Years | 170 | ≤30: ref | Gestational age at GDM diagnosis, pre-pregnancy BMI, FHxT2DM, FPG at diagnosis, homocysteine level
| | | | >30: RR = 2.03 (0.682 – 6.03)
Dacus, 1994^65^ | Age | Years | 100 | <30: ref | None
| | | | ≥30: RR = 0.68 (0.24 – 1.88)
Cheung, 2006^60^ | Age | NR | 102 | NR | Parity, FPG at diagnosis, BMI at index pregnancy, 2-hr OGTT, # prior GDM pregnancies, method of glucose control, FHxT2DM, hospital
Cho, 2006^62^ | Age | Years | 909 | NR | Cho reported 8 models, which adjusted for blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status, and one of the following measures of adiposity at postpartum: BMI, waist circumference, weight, subscapular skin fold thickness, suprailiac skin fold thickness, tricep skin fold thickness, body fat weight, and waist-to-hip ratio. The relative measure for age was not reported in any of the models.
Jang, 2003^63^ | Age | Years | 311 | NR | Pre-pregnancy weight, gestational age at GDM diagnosis, 2-hr glucose, 3-hr insulin on diagnostic OGTT, height, pre-pregnancy BMI, FHxT2DM, postpartum weight
Lobner, 2006^66^ | Age | Years | 302 | NR | GAD and IA-2 antibody status, method of glucose control, BMI at first pregnancy visit, parity, serum CRP
Cheung, 2006^60^ | Hospital | NR | 102 | NR | Age, parity, FPG at diagnosis, BMI at index pregnancy, 2-hr OGTT, # prior GDM pregnancies, method of glucose control, FHxT2DM
Cho, 2006^62^ | Working status | Yes/no | 909 | NR | Cho reported 8 models, which adjusted for blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status, and one of the following measures of adiposity at postpartum: BMI, waist circumference, weight, subscapular skin fold thickness, suprailiac skin fold thickness, tricep skin fold thickness, body fat weight, and waist-to-hip ratio. The relative measure for working status was not reported in any of the models.
Dacus, 1994^65^ | Race | NR | 100 | Other: ref | None
| | | | Black: RR = 1.5 (0.45 – 4.98)

* Includes triglyceride, high density lipoprotein, and low density lipoprotein cholesterol

BMI = body mass index; CI = confidence interval; CRP = C-reactive protein; FHxT2DM = family history of type 2 diabetes; FPG = fasting plasma glucose; GAD = glutamic acid decarboxylase; GDM = gestational diabetes mellitus; hr = hour; NR = not reported; OGTT = oral glucose tolerance test; ref = reference group; RR = relative risk

Evidence Table 20. Studies reporting on the association between parity and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Cheung, 2006^60^ | Parity | NR | 102 | NR | Age, FPG at diagnosis, BMI at index pregnancy, 2-hr OGTT, # prior GDM pregnancies, method of glucose control, FHxT2DM, hospital
Cho, 2006^62^ | Parity | NR | 909 | NR | Cho reported 8 models, which adjusted for blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status, and one of the following measures of adiposity at postpartum: BMI, waist circumference, weight, subscapular skin fold thickness, suprailiac skin fold thickness, tricep skin fold thickness, body fat weight, and waist-to-hip ratio. The relative measure for parity was not reported in any of the models.
Lobner, 2006^66^ | Parity | NR | 302 | 0: ref | GAD and IA-2 antibody status, method of glucose control, BMI at first pregnancy visit, age, serum CRP
| | | | 1–2: RH = 1.2 (0.8 – 1.7; p = 0.45)
| | | | >2: RH = 2.5 (1.1 – 5.3; p = 0.02)
Metzger, 1993^67^ | Parity | NR | 172 | OR = 1.21 (p = 0.09) | 3-hr integrated insulin, obesity

* Includes triglyceride, high density lipoprotein, and low density lipoprotein cholesterol

BMI = body mass index; CI = confidence interval; CRP = C-reactive protein; FHxT2DM = family history of type 2 diabetes mellitus; FPG = fasting plasma glucose; GAD = glutamic acid decarboxylase; GDM = gestational diabetes mellitus; IA-2 = insulinoma antigen-2; NR = not reported; OGTT = oral glucose tolerance test; OR = odds ratio; ref = reference group; RH = relative hazard

Evidence Table 21. Studies reporting on the association between pregnancy-related factors and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Kjos, 1995^68^ | Gestational age at GDM diagnosis | Weeks | 671 | Q1: ref | Postpartum OGTT glucose AUC, antepartum OGTT glucose AUC, highest antepartum fasting glucose
| | | | Q2: RH = 0.66 (0.39 – 1.12)
| | | | Q3: RH = 0.73 (0.45 – 1.18)
| | | | Q4: RH = 0.48 (0.29 – 0.82)
| | | | p = 0.01
Schaefer-Graf, 2002^70^ | Gestational age at GDM diagnosis | Weeks | 1636 | Q1: ref | FPG at diagnosis, class A2, area under the glucose curve of pregnancy OGTT, previous GDM, 50-gm GCT
| | | | Q2: OR = 1.12 (0.72 – 1.74)
| | | | Q3: OR = 0.45 (0.27 – 0.76)
| | | | Q4: OR = 0.35 (0.23 – 0.54)
Cho, 2005^61^ | Gestational age at GDM diagnosis | Weeks | 170 | ≥26 weeks: ref | Age, pre-pregnancy BMI, FHxT2DM, FPG at diagnosis, homocysteine level
| | | | <26 weeks: RR = 2.399 (0.875 – 6.577)
Jang, 2003^63^ | Gestational age at GDM diagnosis | Weeks | 311 | Coefficient = -0.00928 (se = 0.0539) | Pre-pregnancy weight, 2-hr glucose, 3-hr insulin on diagnostic OGTT, age, height, pre-pregnancy BMI, FHxT2DM, postpartum weight
Dacus, 1994^65^ | Gestational age at GDM diagnosis | Weeks | 100 | <24: ref | None
| | | | ≥24: RR = 2.49 (0.9 – 6.88)
Cheung, 2006^60^ | Method of glucose control | Yes/no | 102 | No insulin: ref | Age, parity, FPG at diagnosis, BMI at index pregnancy, 2-hr OGTT, # prior GDM pregnancies, FHxT2DM, hospital
| | | | Insulin: RR = 3.2 (1.6 – 7)
Lobner, 2006^66^ | Method of glucose control | Yes/no | 302 | Diet: ref | GAD and IA-2 antibody status, BMI at first pregnancy visit, parity, age, serum CRP
| | | | Insulin: RH = 4.7 (3.2 – 7.1; p < 0.0001)
Kjos, 1998^69^ | Method of glucose control | NR | 443 | NR | Contraceptive use, AUC at the initial postpartum OGTT, prior OC use, additional pregnancy, postpartum weight loss, duration of OC use
Steinhart, 1997^71^ | Method of glucose control | Yes/no | 88 | No insulin: ref | None
| | | | Insulin: OR = 2.83 (0.8 – 11.2)
Dacus, 1994^65^ | Method of glucose control | Yes/no | 100 | Diet: ref | None
| | | | Insulin: RR = undefined (0 DM treated with diet only)
Cheung, 2006^60^ | Dose of bedtime intermediate-acting insulin required | Insulin units unspecified | 102 | RR = 1.09 (1.03 – 1.17) | fasting blood glucose level
Schaefer-Graf, 2002^70^ | 50-gm GCT | mg/dL | 1636 | Q1: ref | FPG at diagnosis, class A2, area under the glucose curve of pregnancy OGTT, gestational age at GDM diagnosis, previous GDM
| | | | Q2: OR = 2.86 (1.24 – 6.58)
| | | | Q3: OR = 3.82 (1.72 – 8.48)
| | | | Q4: OR = 3.46 (1.57 – 7.64)
Schaefer-Graf, 2002^70^ | Class A2 (any FBG ≥ 105) | Yes/no | 1636 | No: ref | FPG at diagnosis, area under the glucose curve of pregnancy OGTT, gestational age at GDM diagnosis, previous GDM, 50-gm GCT
| | | | Yes: OR = 2.4 (1.22 – 4.72)
Schaefer-Graf, 2002^70^ | Previous GDM | Yes/no | 1636 | No: ref | FPG at diagnosis, class A2, area under the glucose curve of pregnancy OGTT, gestational age at GDM diagnosis, 50-gm GCT
| | | | Yes: OR = 1.63 (1.07 – 2.47)
Cheung, 2006^60^ | # prior GDM pregnancies | NR | 102 | NR | Age, parity, FPG at diagnosis, BMI at index pregnancy, 2-hr OGTT, method of glucose control, FHxT2DM, hospital
Steinhart, 1997^71^ | Spontaneous abortions | Yes/no | 88 | No: ref | None
| | | | Yes: OR = 1.36 (0.5 – 3.5)

AUC = area under the glucose tolerance curve; BMI = body mass index; CI = confidence interval; class A2 = insulin requiring gestational diabetics; CRP = C-reactive protein; DM = diabetes mellitus; FHxT2DM = family history of type 2 diabetes mellitus; FPG = fasting plasma glucose; GAD = glutamic acid decarboxylase; GCT = glucose challenge test; GDM = gestational diabetes mellitus; gm = gram; hr = hour; NR = not reported; OC = oral contraceptive; OGTT = oral glucose tolerance Test; OR = odds ratio; Q = quartile; ref = reference group; RH = relative hazard; RR = relative risk; se = standard error

Evidence Table 22. Studies reporting on the association between postpartum factors and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Peters, 1996^72^ | Additional pregnancy | Yes/no | 666 | No: ref | Postpartum weight change, OGTT glucose area, postpartum BMI, breastfeeding
| | | | Yes: RH = 3.34 (1.8 – 6.19)
Kjos, 1998^69^ | Additional pregnancy | NR | 443 | NR | Contraceptive use, AUC at the initial postpartum OGTT, prior OC use, method of glucose control, postpartum weight loss, duration of OC use
Peters, 1996^72^ | Breastfeeding | Yes/no | 666 | NR | Additional pregnancy, postpartum weight change, OGTT glucose area, postpartum BMI
Xiang, 2006^64^ | Breastfeeding | Yes/no | 526 | NR | Contraceptive use, postpartum BMI, FHxT2DM, HDL cholesterol, triglycerides, weight change during followup
Xiang, 2006^64^ | Breastfeeding | Yes/no | 526 | NR | Interaction term for OC use and triglyceride level, postpartum BMI, FHxT2DM, HDL cholesterol, weight change during followup
Cho, 2006^62^ | Duration of followup | Yes/no | 909 | NR | Cho reported 8 models, which adjusted for blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status, and one of the following measures of adiposity at postpartum: postpartum BMI, waist circumference, weight, subscapular skin fold thickness, suprailiac skin fold thickness, tricep skin fold thickness, body fat weight, and waist-to-hip ratio. The relative measure for duration of followup was not reported in any of the models.
Steinhart, 1997^71^ | Recurrent GDM | Yes/no | 88 | No: ref | None
| | | | Yes: OR = 24.8 (3 – 1132.2)

* Includes triglyceride, high density lipoprotein, and low density lipoprotein cholesterol

AUC = area under the glucose tolerance curve; BMI = body mass index; CI = confidence interval; FHxT2DM = family history of type 2 diabetes mellitus; GDM = gestational diabetes mellitus; HDL = high density lipoprotein; NR = not reported; OC = oral contraceptive; OGTT = oral glucose tolerance test; OR = odds ratio; ref = reference group; RH = relative hazard

Evidence Table 23. Studies reporting on the association between anthropometric measures and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Pallardo, 1999^73^ | Pre-pregnancy BMI | kg/m2 | 788 | ≤27: ref | # of abnormal OGTT results (including fasting), C-peptide glucose score
| | | | >27: OR = 8.66 (2.27 – 32.94; p < 0.01)
Jang, 2003^63^ | Pre-pregnancy BMI | kg/m2 | 311 | NR | Pre-pregnancy weight, gestational age at GDM diagnosis, 2-hr glucose, 3-hr insulin on diagnostic OGTT, age, height, FHxT2DM, postpartum weight
Cho, 2005^61^ | Pre-pregnancy BMI | kg/m2 | 170 | ≤23: ref | Age, gestational age at GDM diagnosis, FHxT2DM, FPG at diagnosis, homocysteine level
| | | | >23: RR = 0.779 (0.27 – 2.246)
Jang, 2003^63^ | Pre-pregnancy weight | kg | 311 | Coefficient = 0.3639 (se = 0.1027) | Gestational age at GDM diagnosis, 2-hr glucose, 3-hr insulin on diagnostic OGTT, age, height, pre-pregnancy BMI, FHxT2DM, postpartum weight
Lobner, 2006^66^ | BMI at first pregnancy visit | kg/m2 | 302 | ≤30: ref | GAD and IA-2 antibody status, method of glucose control, parity, age, serum CRP
| | | | >30: RH = 1.5 (1 – 2.2; p = 0.04)
Metzger, 1993^67^ | Obesity (defined as ≥ 120% of ideal body weight) | % | 172 | OR = 2.83 (p < 0.001) | 3-hr integrated insulin, parity
Cheung, 2006^60^ | BMI at index pregnancy | kg/m2 | 102 | RR = 1.1 (1 – 1.2) | Age, parity, FPG at diagnosis, 2-hr OGTT, # prior GDM pregnancies, method of glucose control, FHxT2DM, hospital
Cho, 2006^62^ | Postpartum BMI | kg/m2 | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 3.34 (1.7 – 6.5)
Cho, 2006^62^ | Postpartum weight | kg | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 3.06 (1.6 – 6)
Jang, 2003^63^ | Postpartum weight | kg | 311 | NR | Pre-pregnancy weight, gestational age at GDM diagnosis, 2-hr glucose, 3-hr insulin on diagnostic OGTT, age, height, pre-pregnancy BMI, FHxT2DM
Cho, 2006^62^ | Postpartum body fat weight | kg | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 3.76 (1.8 – 7.6)
Cho, 2006^62^ | Postpartum subscapular skin fold thickness | mm | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 2.82 (1.4 – 5.6)
Cho, 2006^62^ | Postpartum suprailiac skin fold thickness | mm | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 2.1 (1.2 – 3.7)
Cho, 2006^62^ | Postpartum tricep skin fold thickness | mm | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 2.02 (1.1 – 3.6)
Cho, 2006^62^ | Postpartum waist circumference | cm | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 3.86 (1.8 – 8.2)
Cho, 2006^62^ | Postpartum waist-to-hip ratio | no units | 909 | Lowest quartile: ref | Blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status
| | | | Highest quartile: OR = 3.11 (1.7 – 5.6)
Peters, 1996^72^ | Postpartum BMI | NR | 666 | NR | Additional pregnancy, postpartum weight change, OGTT glucose area, breastfeeding
Xiang, 2006^64^ | Postpartum BMI | kg/m2 | 526 | NR | Contraceptive use, breastfeeding, FHxT2DM, HDL cholesterol, triglycerides, weight change during followup
Xiang, 2006^64^ | Postpartum BMI | kg/m2 | 526 | NR | Interaction term for breastfeeding and OC use, FHxT2DM, triglycerides, HDL cholesterol, weight change during followup
Xiang, 2006^64^ | Postpartum BMI | kg/m2 | 526 | NR | Interaction term for OC use and triglyceride level, FHxT2DM, breastfeeding, HDL cholesterol, weight change during followup
Dacus, 1994^65^ | Postpartum BMI | kg/m2 | 100 | <27: ref | None
| | | | ≥27: RR = 4.11 (0.57 – 29.78)
Peters, 1996^72^ | Postpartum weight change | Per 10 lbs | 666 | RH = 1.95 (1.64 – 2.33) | Additional pregnancy, OGTT glucose area, postpartum BMI, breastfeeding
Kjos, 1998^69^ | Postpartum weight loss | NR | 443 | NR | Contraceptive use, AUC at the initial postpartum OGTT, prior OC use, method of glucose control, additional pregnancy, duration of OC use
Xiang, 2006^64^ | Weight change during followup | NR | 526 | NR | Interaction term for breastfeeding and OC use, postpartum BMI, FHxT2DM, triglycerides, HDL cholesterol
Xiang, 2006^64^ | Weight change during followup | NR | 526 | NR | Interaction term for OC use and triglyceride level, postpartum BMI, FHxT2DM, breastfeeding, HDL cholesterol
Xiang, 2006^64^ | Weight change during followup | NR | 526 | NR | Contraceptive use, postpartum BMI, breastfeeding, FHxT2DM, HDL cholesterol, triglycerides
Jang, 2003^63^ | Height | NR | 311 | NR | Pre-pregnancy weight, gestational age at GDM diagnosis, 2-hr glucose, 3-hr insulin on diagnostic OGTT, age, pre-pregnancy BMI, FHxT2DM, postpartum weight

* Includes triglyceride, high density lipoprotein, and low density lipoprotein cholesterol

AUC = area under the glucose tolerance curve; BMI = body mass index; cm = centimeters; CRP = C-reactive protein; FHxT2DM = family history of type 2 diabetes mellitus; FPG = fasting plasma glucose; GAD = glutamic acid decarboxylase; GDM = gestational diabetes mellitus; HDL = high density lipoprotein; hr = hour; IA-2 = insulinoma antigen-2; kg = kilograms; lbs = pounds; m = meters; mm = millimeters; NR = not reported; OC = oral contraceptive; OGTT = oral glucose tolerance test; OR = odds ratio; ref = reference; RH = relative hazard; RR = relative risk; se = standard error

Evidence Table 24. Studies reporting on the association between oral contraceptive use and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Kjos, 1998^69^ | Contraceptive use | Yes/no | 443 | Combination therapy: ref | AUC at the initial postpartum OGTT, prior OC use, method of glucose control, additional pregnancy, postpartum weight loss, duration of OC use
| | | | Progestin only: RH = 2.87 (1.57 – 5.27)
Xiang, 2006^64^ | Contraceptive use | Yes/no | 526 | COC use: ref | Postpartum BMI, breastfeeding, FHxT2DM, HDL cholesterol, triglycerides, weight change during followup
| | | | DMPA use: RH = 1.07 (0.61 – 1.89; p = 0.81)
Kjos, 1998^69^ | Duration of OC use | Months | 443 | ≤4: RH = 0.72 (0.09 – 5.89) | Contraceptive use, AUC at the initial postpartum OGTT, prior OC use, method of glucose control, additional pregnancy, postpartum weight loss
| | | | 4–8: RH = 2.96 (1.35 – 6.52)
| | | | >8: RH = 4.92 (1.76 – 13.73)
Xiang, 2006^64^ | Interaction term for breastfeeding and OC use | NR | 526 | COC without breastfeeding: ref | Postpartum BMI, FHxT2DM, triglycerides, HDL cholesterol, weight change during followup
| | | | DMPA w/o breastfeeding: RH = 1.06 (0.58 – 1.95; p = 0.85)
| | | | DMPA with breastfeeding: RH = 2.21 (0.96 – 5.11; p = 0.06)
Xiang, 2006^64^ | Interaction term for OC use and triglyceride level | NR | 526 | COC & below median triglyceride: ref | Postpartum BMI, FHxT2DM, breastfeeding, HDL cholesterol, weight change during followup
| | | | COC & above median triglyceride: RH = 1.39 (0.88 – 2.19; p = 0.16)
| | | | DMPA & below median triglyceride: RH = 0.55 (0.22 – 1.31; p = 0.2)
| | | | DMPA & above median triglyceride: RH = 2.28 (1.08 – 4.81; p = 0.03)
Kjos, 1998^69^ | Prior OC use | NR | 443 | NR | Contraceptive use, AUC at the initial postpartum OGTT, method of glucose control, additional pregnancy, postpartum weight loss, duration of OC use

AUC = area under the glucose tolerance curve; BMI = body mass index; CI = confidence interval; COC = combination oral contraception; DMPA = depo-medroxyprogesterone acetate; FHxT2DM = family history of type 2 diabetes mellitus; HDL = high density lipoprotein; NR = not reported; OC = oral contraceptive; OGTT = oral glucose tolerance test; ref = reference group; RH = relative hazard

Evidence Table 25. Studies reporting on the association between metabolic risk factors and the development of type 2 diabetes mellitus following a pregnancy with gestational diabetes

Author, year | Risk factor | Units | N | Measure of association (95% CI) | Covariates included
Cheung, 2006^60^ | Fasting blood glucose level | mmol/L | 102 | RR = 1.37 (1.08 – 1.72) | Dose of bedtime intermediate-acting insulin required
Cheung, 2006^60^ | FPG at diagnosis | mmol/L | 102 | RR = 1.5 (1.3 – 1.9) | Age, Parity, BMI at index pregnancy, 2-hr OGTT, # prior GDM pregnancies, method of glucose control, FHxT2DM, hospital
Steinhart, 1997^71^ | Fasting blood sugar | mmol/L | 88 | ≤5.83: ref | None
| | | | >5.83: OR = 11.05 (2.3 – 103.4)
Cho, 2005^61^ | FPG at diagnosis | mmol/L | 170 | ≤5.3: ref | Age, gestational age at GDM diagnosis, pre-pregnancy BMI, FHxT2DM, homocysteine level
| | | | >5.3: RR = 4.004 (1.405 – 11.409)
Schaefer-Graf, 2002^70^ | FPG at diagnosis | mg/dL | 1636 | Q1: ref | FPG at diagnosis, class A2, area under the glucose curve of pregnancy OGTT, gestational age at GDM diagnosis, previous GDM, 50-gm GCT
| | | | Q2: OR = 7.82 (1.77 – 34.52)
| | | | Q3: OR = 11.13 (2.44 – 50.72)
| | | | Q4: OR = 21.01 (4.58 – 96.29)
Kjos, 1995^68^ | Highest antepartum fasting glucose | mmol/L | 671 | Q1: ref | Postpartum OGTT glucose AUC, gestational age at GDM diagnosis, antepartum OGTT glucose AUC
| | | | Q2: RH= 1.39 (0.7 – 2.75)
| | | | Q3: RH= 2.09 (1.12 – 3.9)
| | | | Q4: RH= 2.47 (1.25 – 4.9)
Pallardo, 1999^73^ | # of abnormal OGTT results (including fasting) | NR | 788 | OR = 3.03 (1.43 – 6.37; p = <0.01) | Pre-pregnancy BMI, C-peptide glucose score
Steinhart, 1997^71^ | GTT total | mmol/L | 88 | ≤41.63: ref | None
| | | | >41.63: OR = 15.5 (2 – 678)
Buchanan, 1999^74^ | 1-hr plasma glucose, diagnostic OGTT | mmol/L | 91 | Lowest tertile: ref | Beta-cell compensation index, basal glucose production rate
| | | | Highest tertile: OR = 15.2 (1.4 – 166.3)
Buchanan, 1999^74^ | 1-hr plasma glucose, diagnostic OGTT | mmol/L | 91 | Lowest tertile: ref | OGTT 30-min incremental insulin:glucose, basal glucose production rate, clamp SI
| | | | Highest tertile: OR = 22 (1.5 – 328.5)
Jang, 2003^63^ | 2-hr glucose | mmol/L | 311 | Coefficient = 0.0156 (se = 0.0075) | Pre-pregnancy weight, gestational age at GDM diagnosis, 3-hr insulin on diagnostic OGTT, age, height, pre-pregnancy BMI, FHxT2DM, postpartum weight
Metzger, 1993^67^ | 2-hr glucose | mmol/L | 177 | OR = 1.03 (p < 0.001) | OGTT 30-min stimulated insulin secretion, basal insulin
Cheung, 2006^60^ | 2-hr OGTT | mmol/L | 102 | RR = 1.3 (1.1 – 1.4) | Age, parity, FPG at diagnosis, BMI at index pregnancy, # prior GDM pregnancies, method of glucose control, FHxT2DM, hospital
Jang, 2003^63^ | 3-hr insulin on diagnostic OGTT | Pmol/L | 311 | OR = 0.98 (0.96–0.99) | Pre-pregnancy weight, gestational age at GDM diagnosis, 2-hr glucose, age, height, pre-pregnancy BMI, FHxT2DM, postpartum weight
Metzger, 1993^67^ | 3-hr integrated insulin | pM.min | 172 | NR (p < 0.01) | 3-hr integrated insulin, parity, obesity
Buchanan, 1998^75^ | Antepartum 30 minutes incremental plasma insulin/glucose ratio | NR | 122 | NR (p = 0.002) | Total AUC for diagnostic antepartum 100-gm OGTT glucose
Buchanan, 1999^74^ | OGTT 30-min incremental insulin:glucose | NR | 91 | lowest tertile: ref | Incremental glucose area diagnostic OGTT, FSIGT acute insulin response, basal glucose production rate, clamp SI
| | | | highest tertile: OR = 0.1 (0.005 – 2.2)
Buchanan, 1999^74^ | OGTT 30-min incremental insulin:glucose | NR | 91 | lowest tertile: ref | 1-hr plasma glucose diagnostic OGTT, basal glucose production rate, clamp SI
| | | | highest tertile: OR = 0.08 (0.005 – 1.1)
Kjos, 1995^68^ | Antepartum OGTT glucose AUC (mmol per min/l) | mmol/l. min. -1 | 671 | Q1: ref | Postpartum OGTT glucose AUC, gestational age at GDM diagnosis, highest antepartum fasting glucose
| | | | Q2: RH = 1.13 (0.58 – 2.22)
| | | | Q3: RH = 1.42 (0.77 – 2.62)
| | | | Q4: RH = 2.13 (1.18 – 3.85)
| | | | p = 0.004
Schaefer-Graf, 2002^70^ | Area under the glucose curve of pregnancy OGTT | g.min/dL | 1636 | Q1: ref | FPG at diagnosis, class A2, gestational age at GDM diagnosis, previous GDM, 50-gm GCT
| | | | Q2: OR = 0.93 (0.41 – 2.13)
| | | | Q3: OR = 1.47 (0.73 – 2.99)
| | | | Q4: OR = 3.64 (1.93 – 6.84)
Buchanan, 1998^75^ | Total AUC for diagnostic antepartum 100-gm OGTT glucose | NR | 122 | NR (p = 0.003) | Antepartum 30 minutes incremental plasma insulin/glucose
Buchanan, 1999^74^ | Incremental glucose area, diagnostic OGTT | min/mol/L | 91 | lowest tertile: ref | FSIGT acute insulin response, OGTT 30-min incremental insulin:glucose, basal glucose production rate, clamp SI
| | | | highest tertile: OR = 15 (1.1 – 207.9)
Peters, 1996^72^ | OGTT glucose area | NR | 666 | NR | Additional pregnancy, postpartum weight change, postpartum BMI, breastfeeding
Kjos, 1998^69^ | AUC at the initial postpartum OGTT | NR | 443 | NR | Contraceptive use, prior OC use, method of glucose control, additional pregnancy, postpartum weight loss, duration of OC use
Kjos, 1995^68^ | Postpartum OGTT glucose AUC | mmol/l. min. -1 | 671 | Q1: ref | Gestational age at GDM diagnosis, antepartum OGTT glucose AUC, highest antepartum fasting glucose
| | | | Q2: RH = 2.67 (1 – 7.25)
| | | | Q3: RH = 5.53 (2.16 – 14.16)
| | | | Q4: RH = 11.48 (4.52 – 29.14)
| | | | p < 0.0001
Buchanan, 1999^74^ | Basal glucose production rate | mmol.min.m2 | 91 | Lowest tertile: ref | Incremental glucose area, diagnostic OGTT, FSIGT acute insulin response, OGTT 30-min incremental insulin:glucose, clamp SI
| | | | Highest tertile: OR = 7
Buchanan, 1999^74^ | Basal glucose production rate | mmol.min.m2 | 91 | Lowest tertile: ref | 1-hr plasma glucose diagnostic OGTT, beta-cell compensation index
| | | | Highest tertile: OR = 5.3 (0.63 – 44.4)
Buchanan, 1999^74^ | Basal glucose production rate | mmol.min.m2 | 91 | Lowest tertile: ref | 1-hr plasma glucose diagnostic OGTT, OGTT 30-min incremental insulin:glucose, clamp SI
| | | | Highest tertile: OR = 6.8 (0.7 – 65.5)
Buchanan, 1999^74^ | Beta-cell compensation index | NR | 91 | Lowest tertile: ref | 1-hr plasma glucose diagnostic OGTT, basal glucose production rate
| | | | Highest tertile: OR = 0.09 (0.009 – 0.09)
Buchanan, 1999^74^ | Clamp SI | mmol.min.m2/microU/ml*1000 | 91 | Lowest tertile: ref | 1-hr plasma glucose diagnostic OGTT, OGTT 30-min incremental insulin:glucose, basal glucose production rate
| | | | Highest tertile: OR = 0.18 (0.03 – 1.2)
Buchanan, 1999^74^ | Clamp SI | mmol.min.m2/micro U/ml*1000 | 91 | Lowest tertile: ref | Incremental glucose area, diagnostic OGTT, FSIGT acute insulin response, OGTT 30-min incremental insulin:glucose, basal glucose production rate
| | | | Highest tertile: OR = 0.15 (0.02 – 1.2)
Buchanan, 1999^74^ | FSIGT acute insulin response | mmol/l.min | 91 | Lowest tertile: ref | Incremental glucose area, diagnostic OGTT, OGTT 30-min incremental insulin:glucose, basal glucose production rate, clamp SI
| | | | Highest tertile: OR = 0.08 (0.005 – 1)
Pallardo, 1999^73^ | C-peptide glucose score | mmol/L | 788 | OR = 0.46 (0.25 – 0.85; p < 0.05) | Pre-pregnancy BMI, # of abnormal OGTT results (including fasting)
Xiang, 2006^64^ | HDL cholesterol | mg/dL | 526 | NR | Contraceptive use, postpartum BMI, breastfeeding, FHxT2DM, triglycerides, weight change during followup
Cho, 2006^62^ | Blood pressure | NR | 909 | NR | Cho reported 8 models, which adjusted for blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status, and one of the following measures of adiposity at postpartum: BMI, waist circumference, weight, subscapular skin fold thickness, suprailiac skin fold thickness, tricep skin fold thickness, body fat weight, and waist-to-hip ratio. The relative measure for blood pressure was not reported in any of the models.
Xiang, 2006^64^ | HDL cholesterol | mg/dL | 526 | NR | Interaction term for breastfeeding and OC use, postpartum BMI, FHxT2DM, triglycerides, weight change during followup
Xiang, 2006^64^ | HDL cholesterol | mg/dL | 526 | NR | Interaction term for OC use and triglyceride level, postpartum BMI, FHxT2DM, breastfeeding, weight change during followup
Xiang, 2006^64^ | Triglycerides | mg/dL | 526 | NR | Contraceptive use, postpartum BMI, breastfeeding, FHxT2DM, HDL cholesterol, weight change during followup
Xiang, 2006^64^ | Triglycerides | mg/dL | 526 | NR | Interaction term for breastfeeding and OC use, postpartum BMI, FHxT2DM, HDL cholesterol, weight change during followup
Cho, 2006^62^ | Lipid profile which includes triglycerides, HDL and LDL cholesterol | NR | 909 | NR | Cho reported 8 models, which adjusted for blood pressure, lipid profile*, age, duration of followup, parity, FHxT2DM, working status, and one of the following measures of adiposity at postpartum: BMI, waist circumference, weight, subscapular skin fold thickness, suprailiac skin fold thickness, tricep skin fold thickness, body fat weight, and waist-to-hip ratio. The relative measure for the lipid profile was not reported in any of the models.
Cho, 2005^61^ | Homocysteine level at baseline 6 weeks postpartum | mmol | 170 | ≤6.38: ref | Age, gestational age at GDM diagnosis, pre-pregnancy BMI, FHxT2DM, FPG at diagnosis
| | | | >6.38: RR = 3.555 (1.059 – 11.934)
Lobner, 2006^66^ | GAD and IA-2 antibody status | NR | 302 | both GAD and IA-2 antibody negative: ref | Method of glucose control, BMI at first pregnancy visit, parity, age, serum CRP
| | | | GAD or IA-2 antibody positive: RH = 4.1 (2.6 – 6.7; p < 0.0001)
Metzger, 1993^67^ | Basal insulin | NR | 177 | OR = 0.19 (p < 0.0001) | 2-hr glucose, OGTT 30-min stimulated insulin secretion
Metzger, 1993^67^ | OGTT 30-min stimulated insulin secretion | NR | 177 | OR = 0.07 (p = 0.07) | 2-hr glucose, basal insulin
Lobner, 2006^66^ | Serum CRP | mg/L | 302 | ≤0.8: ref | GAD and IA-2 antibody status, method of glucose control, BMI at first pregnancy visit, parity, age
| | | | >0.8: RH = 1.2 (0.7 – 2.2; p = 0.47)

AUC = area under the glucose tolerance curve; BMI = body mass index; CI = confidence interval; class A2 = insulin-requiring gestational diabetics; CRP = C = reactive protein; dL = deciliter; FHxT2DM = family history of type 2 diabetes mellitus; FPG = fasting plasma glucose; FSIGT = frequently sampled intravenous glucose tolerance; GAD = glutamic acid decarboxylase; GDM = gestational diabetes mellitus; gm = grams; GTT = glucose tolerance test; HDL = high density lipoprotein; hr = hour; L = liter; m = meters; min = minutes; mg = milligram; mmol = millimole; NR = not reported; OC = oral contraceptive; OGTT = oral glucose tolerance test; OR = odds ratio; ref = reference; Q = quartile; RH = relative hazard; RR = relative risk; se = standard error; SI = sensitivity index

Evidence Table 26. Grading of the body of evidence on the association of risk factors with the development of type 2 diabetes following a pregnancy with gestational diabetes (KQ3)

| Family history type 2 diabetes | Sociodemographics | Maternal lifestyle | Parity | Pregnancy-related factors
[underlined: Quantity of Evidence:] | 5 | 6 | 0 | 4 | 9
Number of studies
Total number of patients studied | 2018 | 1894 | 0 | 1485 | 3823
[underlined: Quality and Consistency of Evidence:] | low | medium | | high | high
Were the study designs mostly [underlined: high quality] (e.g., cohort study or case-control study with multivariate adjustment for most or all major potential confounding factors), [underlined: medium quality] (e.g., cohort study or case-control study with adjustment for only a few major potential confounding factors), or [underlined: low quality] (e.g., no multivariate adjustment for confounding factors)?
Did the studies have other serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | | 0 | 0
Did the studies have important inconsistency? (-1) | 0 | -1 | | 0 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, risk factors, and outcomes are similar to those of interest)? | 0 | 0 | | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | | -1 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | | 0 | 0
Did the studies show strong evidence of association between the risk factors and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | -1 | -1 | | 0 | 0
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | | +1 | 0
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | 0 | +1 | | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | very low | low | very low | low | moderate

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research [underlined: is likely to] have an important impact on our confidence in the estimate of effect and is likely to change the estimate; very low = any estimate of effect is very uncertain.

Evidence Table 26a. Grading of the body of evidence on the association of risk factors with the development of type 2 diabetes following a pregnancy with gestational diabetes (KQ3)

| Postpartum factors | Measures of anthropometry | Oral contraceptive use | Metabolic risk factors
[underlined: Quantity of Evidence:] | 5 | 11 | 2 | 15
Number of studies
Total number of patients studied | 2632 | 4489 | 969 | 7002
[underlined: Quality and Consistency of Evidence:] | medium | medium | Medium | medium
Were the study designs mostly [underlined: high quality] (e.g., cohort study or case-control study with multivariate adjustment for most or all major potential confounding factors), [underlined: medium quality] (e.g., cohort study or case-control study with adjustment for only a few major potential confounding factors), or [underlined: low quality] (e.g., no multivariate adjustment for confounding factors)?
Did the studies have other serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | 0 | 0 | 0 | 0
Did the studies have important inconsistency? (-1) | -1 | 0 | -1 | 0
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, risk factors, and outcomes are similar to those of interest)? | 0 | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | 0 | 0 | 0
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0 | 0
Did the studies show strong evidence of association between the risk factors and outcome? (“strong” if significant relative risk or odds ratio > 2 based on consistent evidence from 2 or more studies with no plausible confounders (+1); “very strong” if significant relative risk or odds ratio > 5 based on direct evidence with no major threats to validity (+2)) [underlined: - use your clinical judgment for absolute differences.] | 0 | +1 | 0 | +1
Did the studies have evidence of a dose-response gradient? (+1) | 0 | 0 | 0 | +1
Did the studies have unmeasured plausible confounders that most likely reduced the magnitude of the observed association? (+1) | +1 | 0 | 0 | +1
Overall grade of evidence (high, moderate, low, very low) | very low | moderate | low | moderate

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: is likely to] change the estimate; very low = any estimate of effect is very uncertain.

Evidence Table 27. Characteristics of studies evaluating the performance characteristics of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes

Author, year | Study design | Exclusion criteria | Time since delivery | Mean age (in years) (Age range) | Race, n (%) | Weight (in kg) / BMI (in kg/m^2^), mean | Reference test* | Comparison test* | Loss to followup
Country
Agarwal, 2004^95^ | Retrospective | NR | (range: 4–8 weeks) | 32 | Arab: (78.8) | NR | A, B | C | 67%
United Arab Emigrates | | | | | Indian Nationals: (20.5)
Conway, 1999^97^ | Prospective | NR | Median: 6-weeks (range: 4–13 weeks) | NR | NR | NR | A | B | 82%
US
Costa, 2000^100^ | Prospective | NR | (range: 2–12 months) | ND: 33.9 | C: 120 (100) | Post-pregnancy | A | C | NR
Spain | | | | IGT or T2DM: 36 | | BMI:
| | | | | | ND: 25.1
| | | | | | IGT or T2DM: 28.5
Cypryk, 2004^98^ | Retrospective | Known T1DM and T2DM (23%) since delivery | Mean: 3.1 years (range 0.5–8 years) | 34.3 | C: (100) | NR | A | C | 66%
Poland
Holt, 2003^96^ | Retrospective | NR | 6 weeks | 31.1 (18.7 – 38.9) | C: (86) | NR | A | C | 20%
United Kingdom | | | | | Asian: (14)
Kousta, 1999^101^ | Prospective | Known T2DM (14%) since delivery | Median: 28 months (range: 1–86 months) | 36.6 | European: 68 (35) | Pre-pregnancy | A | B, C | NR
United Kingdom | | | | | Asian: 56 (29) | BMI: 28.1
| | | | | Afro-Caribbean: 32 (17)
| | | | | Other: 36 (19)
Reichelt, 2002^99^ | Prospective | NR | Mean: 5.7 years (range 4–8 years) | NR | NR | NR | B | C | 26%
Brazil
Reinblatt, 2006^94^ | Retrospective | NR | (range: 6 weeks–6 months) | 32 (15–45) | NR | Pre-pregnancy | B | C | 79%
Canada | | | | | | BMI: 25.6

* A= FBG > 7.8 mmol/L (140 mg/dL) or 2-hr plasma glucose after 75-gm OGTT > 11.1 mmol/L (200 mg/dL); B = FBG > 7.0 mmol/L (126 mg/dL) or 2-hr plasma glucose after 75-gm OGTT > 11.1 mmol/L (200 mg/dL); C = FBG > 7.0 mmol/L (126 mg/dL)

Asian = Asian or Asian American; BMI = body mass index; C = Caucasian; dL = deciliter; FBG = fasting blood glucose; gm = gram; hr = hour; IGT = impaired glucose tolerance; kg = kilogram; L = liter; m = meter; mg = milligram; mmol = millimole; ND = nondiabetic; NR = not reported; OGTT = oral glucose tolerance test; US = United States; T1DM = type 1 diabetes mellitus; T2DM = type 2 diabetes mellitus

Evidence Table 28. Performance characteristics of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes

Author, year | True positive | False positive | False negative | True negative | Total | Sensitivity (%) | 95% CI | Specificity (%) | 95% CI
Comparison 1:
Reference test: FBG > 7.8 mmol/L (140 mg/dL) or 2-hr plasma glucose after 75-gm OGTT > 11.1 mmol/L (200 mg/dL)
Comparison test: FBG > 7.0 mmol/L (126 mg/dL) or 2-hr plasma glucose after 75-gm OGTT > 11.1 mmol/L (200 mg/dL)
Conway, 1999^97^ | 11 | 3 | 0 | 165 | 179 | 100* | n/a | 98 | 95, 100
Kousta, 1999^101^ | 22 | 3 | 0 | 140 | 165 | 100* | n/a | 98 | 94, 100
Comparison 2:
Reference test: FBG > 7.0 mmol/L (126 mg/dL) or 2-hr plasma glucose after 75-gm OGTT > 11.1 mmol/L (200 mg/dL)
Comparison test: FBG > 7.0 mmol/L (126 mg/dL)
Reinblatt, 2006^94^ | 12 | 0 | 14 | 249 | 275 | 46 | 27, 66 | 100* | n/a
Agarwal, 2004^95^ | 36 | 0 | 14 | 499 | 549 | 72 | 58, 84 | 100* | n/a
Reichelt, 2002^99^ | 8 | 0 | 1 | 108 | 117 | 89 | 52, 100 | 100* | n/a
Comparison 3:
Reference test: FBG > 7.8 mmol/l (140 mg/dL) or 2-hr plasma glucose after 75-gm OGTT > 11.1 mmol/l (200 mg/dL)
Comparison test: FBG > 7.0 mmol/l (126 mg/dL)
Agarwal, 2004^95^ | 31 | 5 | 14 | 499 | 549 | 69 | 53, 82 | 99 | 98, 100
Cypryk, 2004^98^ | 1 | 2 | 6 | 139 | 148 | 14 | 0.04, 58 | 99 | 95, 100
Holt, 2003^96^ | 3 | 7 | 0 | 112 | 122 | 100 | 29, 100 | 94 | 88, 98
Costa, 2000^100^ | 2 | 1 | 0 | 117 | 120 | 100 | 16, 100 | 99 | 95, 100
Kousta, 1999^101^ | 16 | 3 | 6 | 140 | 165 | 73 | 50, 89 | 98 | 94, 100

* Fixed at 100% by definition of test criteria.

CI = confidence interval; dL = deciliter; FBG = fasting blood glucose; gm = gram; hr = hour; L = liter; mg = milligram; mmol = millimole; n/a = not applicable; OGTT = oral glucose tolerance test

Evidence Table 29. Quality of studies evaluating the performance characteristics of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes

Author, year | Data collection | Patient selection | Loss to followup | Disease spectrum | Report of test reproducibility | Calculation of test reproducibility
Agarwal, 2004^95^ | Retrospective | Consecutive | 67% | Clinical population | Laboratory methods reported | None
Conway, 1999^97^ | Retrospective | Consecutive | 82% | Clinical population | Laboratory methods reported | None
Costa, 2000^100^ | Prospective | NR | NR | Clinical population | Laboratory methods reported | None
Cypryk, 2004^98^ | Prospective | Consecutive | 33% | Clinical population | NR | None
| | | | Excluded T1/2 DM diagnosed after delivery (23%)
Holt, 2003^96^ | Retrospective | Consecutive | 20% | Clinical population | Yes | Yes
Kousta, 1999^101^ | Prospective | Consecutive | NR | Clinical population | Laboratory methods reported | Other reference cited
| | | | Excluded T2DM diagnosed after delivery (14%)
Reichelt, 2002^99^ | Prospective | Consecutive | 26% | Clinical population | NR | None
Reinblatt, 2006^94^ | Retrospective | Consecutive | 79% | Clinical population | NR | Other reference cited

NR = not reported; T1DM = type 1 diabetes mellitus; T2DM = type 2 diabetes mellitus

Evidence Table 30. Grading of the body of evidence of the performance characteristics of tests for diagnosing type 2 diabetes following a pregnancy with gestational diabetes (KQ4)

| Comparison 1* | Comparison 2† | Comparison 3‡
[underlined: Quantity of evidence:] | 2 | 3 | 5
Number of studies
Total number of patients studied | 344 | 941 | 1104
[underlined: Quality and consistency of evidence:] | Medium | Medium | Medium
Were the study designs mostly [underlined: high quality] (e.g., prospective, independent comparison of a test to a reference test), [underlined: medium quality] (e.g., retrospective, independent comparison of a test to a reference test), or [underlined: low quality] (e.g., no independent comparison)?
Did the studies have other serious (-1) or very serious (-2) limitations in quality? (Enter 0 if none) | -1 | -1 | -1
Did the studies have important inconsistency? (-1) | 0 | -1 | -1
Was there some (-1) or major (-2) uncertainty about the directness (i.e. extent to which the people, tests and outcomes are similar to those of interest)? | 0 | 0 | 0
Were data imprecise or sparse? (-1) (i.e. lack of data or very wide confidence intervals that may change conclusions) | -1 | -1 | -1
Did the studies have high probability of reporting bias? (-1) | 0 | 0 | 0
Overall grade of evidence (high, moderate, low, very low) | Very low | Very low | Very low

High = further research is very unlikely to change our confidence in the estimates; moderate = further research is likely to have an important impact on our confidence in the estimate of effect and [underlined: may] change the estimate; low = further research [underlined: is likely to] have an important impact on our confidence in the estimate of effect and is likely to change the estimate; very low = any estimate of effect is very uncertain.

* Comparison 1: Reference test: Fasting blood glucose > 7.8 mmol/L (140 mg/dL) or 2-hr plasma glucose after 75 gm OGTT > 11.1 mmol/L (200 mg/dL)

Comparison test: Fasting blood glucose > 7.0 mmol/L (126 mg/dL) or 2-hr plasma glucose after 75 gm OGTT > 11.1 mmol/L (200 mg/dL)

† Comparison 2: Reference test: Fasting blood glucose > 7.0 mmol/L (126 mg/dL) or 2-hr plasma glucose after 75 gm OGTT > 11.1 mmol/L (200 mg/dL)

Comparison test: Fasting blood glucose > 7.0 mmol/L (126 mg/dL)

‡ Comparison 3: Reference test: Fasting blood glucose > 7.8 mmol/l (140 mg/dL) or 2-hr plasma glucose after 75 gm OGTT > 11.1 mmol/l (200 mg/dL)

Comparison test: Fasting blood glucose > 7.0 mmol/l (126 mg/dL)