# Appendix E: Sample Data Abstraction Forms

To see the Sample Data Abstraction Forms, please select the link below. This link will take you to a PDF version of the forms.

Sample Data Abstraction Forms