# Appendix D: List of Excluded Studies

## References

1 National Diabetes Month. Reviewing the types of diabetes. Diabetes Self Manag 2006;23(6):38, 40–2. Does not include original data
2 Anonymous. Gestational diabetes mellitus. Diabetes Care 2004;27 (Suppl 1):S88–90. Does not include original data
3 Anonymous. Gestational diabetes mellitus. Diabetes Care 2003;26 (Suppl 1):S103–5. Does not include original data
4 Anonymous. Pregnancy problems echo later in life. Harv Heart Lett 2002;13(4):7. Does not include original data
5 Anonymous. Gestational diabetes mellitus. Diabetes Care 2000;23 (Suppl 1):S77–9. Does not include original data
6 Anonymous. Induction of labour at term (versus expectant management) for macrosomia results in which one of the following? Decreased birth weight. Can Fam Physician 1998;44:1610, 1619–20. Does not include original data
7 Anonymous. From the Centers for Disease Control and Prevention. Prenatal care, pregnancies complicated by diabetes. JAMA 1993;269(15):1932. Does not apply to a key question
8 Anonymous. Sulphonylureas in pregnancy. Lancet 1991;338(8776):1222. Does not include original data
9 Anonymous. Diabetes in pregnancy. Baillieres Clin Obstet Gynaecol 1991;5(2):257–503. Other
10 Anonymous. Diabetes in pregnancy. Clin Obstet Gynecol 1985;28(3):455–568. Does not include original data
11 Anonymous. Insulin pump shows promise for pregnant women—but problems for children. Am Pharm 1986;NS26(4):9–10. Does not include a medication of interest for KQ1
12 Anonymous. The lack of drug studies in pregnancy currently restricts treatment options to insulin for gestational diabetes. Drugs Ther. Perspect. 2004;20(6):17–20. Does not include original data
13 Anonymous. Use of glibenclamide in gestational diabetes. Pharm. J. 2000;265(7120):644. Does not include original data
14 Anonymous. Diabetes and congenital abnormalities. Bandolier 2006;13(3):5. Does not apply to a key question
15 Anonymous. Gestational diabetes mellitus. Canadian Journal of Diabetes 2003;27S99–105. Does not include original data
16 Anonymous. Diet, exercise delay type 2 diabetes. FDA Consumer 2001;35(5):10–11. Does not apply to a key question
17 Anonymous. Glyburide vs insulin for gestational diabetes. Nurses' Drug Alert 2000;24(12):91. Does not include original data
18 Anonymous. Insulin for gestational diabetes. Emergency Medicine 1990;22(17):45. Does not include original data
19 Anonymous. Reducing the risks in gestational diabetes. Emergency Medicine 1990;22(3):113. Does not include original data
20 Abell DA, Beischer NA, Wood C. Routine testing for gestational diabetes, pregnancy hypoglycemia and fetal growth retardation, and results of treatment. J Perinat Med. 1976;4(4):197-212. Diagnosis of gestational diabetes not confirmed. [pmid: 1011060].
21 Aberg AE, Jonsson EK, Eskilsson I, et al. Predictive factors of developing diabetes mellitus in women with gestational diabetes. Acta Obstet Gynecol Scand. 2002;81(1):11-6. Does not evaluate risk factors for type 2 diabetes. [pmid: 11942881].
22 Adam PA, Schwartz R. Diagnosis and treatment: should oral hypoglycemic agents be used in pediatric and pregnant patients?. Pediatrics. 1968;42(5):819-823. Does not include original data. [pmid: 5685363].
23 Agarwal S, Gupta AN. Gestational diabetes. J Assoc Physicians India. 1982;30(4):203-5. No appropriate comparison group for KQ1. [pmid: 6763613].
24 Agrawal RK, Lui K, Gupta JM. Neonatal hypoglycaemia in infants of diabetic mothers. J Paediatr Child Health. 2000;36(4):354-6. Does not have a comparison of interest. [pmid: 10940170].
25 Akiel AS, Laajam MA, Moghraby S, et al. Clinical experience with diabetic pregnancy in Riyadh: Analysis of 357 cases. Ann Saudi Med. 1990;10(3):308-312. No appropriate comparison group for KQ1.
26 al-Najashi SS. Control of gestational diabetes. Int J Gynaecol Obstet. 1995;49(2):131-5. Other. [pmid: 7649316].
27 Albareda M, Caballero A, Badell G, et al. Diabetes and abnormal glucose tolerance in women with previous gestational diabetes. Diabetes Care. 2003;26(4):1199-205. Does not evaluate risk factors for type 2 diabetes. [pmid: 12663597].
28 Albareda M, Caballero A, Badell G, et al. Metabolic syndrome at follow-up in women with and without gestational diabetes mellitus in index pregnancy. Metabolism. 2005;54(8):1115-21. No relevant risk factor for KQ3. [pmid: 16092064].
29 Albareda M, De Leiva A, Corcoy R. Reproducibility of diabetes mellitus diagnosis (WHO 1999 criteria) in women. Acta Diabetol. 2004;41(1):14-17. Not evaluating people with gestational diabetes. [pmid: 15057549].
30 Aldridge V, Temple R. Improving outcomes in diabetic pregnancies — a challenge for all. Diabetes Primary Care. 2000;2(2):38-41. Other.
31 Ali Z, Alexis SD. Occurrence of diabetes mellitus after gestational diabetes mellitus in Trinidad. Diabetes Care. 90;13(5):527-9. Does not evaluate risk factors for type 2 diabetes. [pmid: 2351031].
32 Altman JJ, Brun JM, Chanson P, et al. Multicenter survey of diabetic pregnancy in France. Diabetes Care. 91;14(11):994-1000. Does not apply to a key question. [pmid: 1797514].
33 Alur P, Kodiyanplakkal P, Del Rosario A, et al. Epidemiology of infants of diabetic mothers in indigent Micronesian population-Guam experience. Pac Health Dialog. 2002;9(2):219-221. Diagnosis of gestational diabetes not confirmed. [pmid: 14736104].
34 Arnold JM, Bromham DR, Burke BJ. Induction of labour in pregnant diabetics using vaginal prostaglandin E2 pessaries. J Obstet Gynaecol. 1982;3(2):75-78. Does not apply to a key question.
35 Athukorala C, Crowther CA, Willson K. Women with gestational diabetes mellitus in the ACHOIS trial: Risk factors for shoulder dystocia. Aust N Z J Obstet Gynaecol. 2007;47(1):37-41. Does not apply to a key question. [pmid: 17261098].
36 Banerjee S, Ghosh US, Banerjee D. Effect of tight glycaemic control on fetal complications in diabetic pregnancies. J Assoc Physicians India. 2004;52:109-13. Does not apply to a key question. [pmid: 15656043].
37 Banerjee S, Ghosh U S, Banerjee D. Foetomaternal complications in pregnancies with diabetes mellitus: association with the amount of insulin requirement, mean terminal blood glucose and HbA1C levels. J Indian Med Assoc 2003;101(12):728, 730–2, 740. No appropriate comparison group for KQ1
38 Banerjee T. Diabetes in pregnancy. J Indian Med Assoc. 76;67(11):247-50. Does not include original data. [pmid: 1025219].
39 Barahona MJ, Sucunza N, Garcia-Patterson A, et al. Period of gestational diabetes mellitus diagnosis and maternal and fetal morbidity. Acta Obstet Gynecol Scand. 2005;84(7):622-7. No appropriate comparison group for KQ1. [pmid: 15954869].
40 Barnett RV. Diabetes in pregnancy. The obstetrician's dilemma. Ala J Med Sci. 1972;9(3):282-8. Does not include original data. [pmid: 5074659].
41 Bartha JL, Martinez-del-Fresno P, Comino-Delgado R. Postpartum metabolism and autoantibody markers in women with gestational diabetes mellitus diagnosed in early pregnancy. Am J Obstet Gynecol. 2001;184(5):965-70. Does not report a relative measure. [pmid: 11303206].
42 Bassaw B, Ataullah I, Roopnarinesingh S, et al. Diabetes in pregnancy. Int J Gynaecol Obstet. 1995;50(1):5-9. Does not apply to a key question. [pmid: 7556860].
43 Bastian JS. Diabetic control in pregnancy. Am J Obstet Gynecol. 1988;158(3 Pt 1):677-678. Does not include original data. [pmid: 3348331].
44 Bates GW. Management of gestational diabetes. Postgrad Med. 1974;55(6):55-8. Does not include original data. [pmid: 4831491].
45 Beischer NA, Cookson T, Sheedy M, et al. Norethisterone and gestational diabetes. Aust N Z J Obstet Gynaecol. 1992;32(3):233-8. Diagnosis of gestational diabetes not confirmed. [pmid: 1445134].
46 Beischer NA, Wein P, Sheedy MT, et al. Studies of postnatal diabetes mellitus in women who had gestational diabetes. Part 1. Estimation of the prevalence of unrecognized prepregnancy diabetes mellitus. Aust N Z J Obstet Gynaecol. 1997;37(4):412-9. No relevant risk factor for KQ3. [pmid: 9429703].
47 Beischer NA, Wein P, Sheedy MT, et al. Prevalence of antibodies to glutamic acid decarboxylase in women who have had gestational diabetes. Am J Obstet Gynecol. 1995;173(5):1563-9. Diagnosis of gestational diabetes not confirmed. [pmid: 7503202].
48 Bellmann O. Therapy of gestational diabetes. Acta Endocrinol Suppl (Copenh). 1986;277:50-5. Does not have a comparison of interest. [pmid: 3532670].
49 Ben Slama C, Nsiri B, Bouguerra R, et al. Diabetic pregnancy in over 35 years old women. Ann Ist Super Sanita. 1997;33(3):313-6. Does not apply to a key question. [pmid: 9542254].
50 Benito JA, Melchor JC, Cortazar A, et al. Gestational diabetes: maternal profile and perinatal outcome according to the insulin therapy. Prog Obstet Ginecol. 1996;39(2):103-108. Not written in English.
51 Benjamin E, Winters D, Mayfield J, et al. Diabetes in pregnancy in Zuni Indian women. Prevalence and subsequent development of clinical diabetes after gestational diabetes. Diabetes Care. 1993;16(9):1231-5. Other. [pmid: 8404425].
52 Berkowitz GS, Roman SH, Lapinski RH, et al. Maternal characteristics, neonatal outcome, and the time of diagnosis of gestational diabetes. Am J Obstet Gynecol. 1992;167(4 Pt 1):976-82. Does not apply to a key question. [pmid: 1415436].
53 Bernstein IM, Catalano PM. Examination of factors contributing to the risk of cesarean delivery in women with gestational diabetes. Obstet Gynecol. 1994;83(3):462-5. No appropriate comparison group for KQ1. [pmid: 8127543].
54 Bevier WC, Jovanovic-Peterson L, Burns A, et al. Blood pressure predicts insulin requirement and exogenous insulin is associated with increased blood pressure in women with gestational diabetes mellitus. Am J Perinatol. 1994;11(5):369-73. Does not have a comparison of interest. [pmid: 7993522].
55 Bhattacharyya A, Vice PA. Insulin lispro, pregnancy, and retinopathy. Diabetes Care. 1999;22(12):2101-2104. Not evaluating people with gestational diabetes. [pmid: 10587864].
56 Bhattacharyya A, Brown S, Hughes S, et al. Insulin lispro and regular insulin in pregnancy. QJM. 2001;94(5):255-60. Diagnosis of gestational diabetes not confirmed. [pmid: 11353099].
57 Blackwell SC, Hassan SS, Wolfe HW, et al. Why are cesarean delivery rates so high in diabetic pregnancies?. J Perinat Med. 2000;28(4):316-20. No appropriate comparison group for KQ1. [pmid: 11031703].
58 Bloomgarden ZT. Aspects of type 2 diabetes and related insulin-resistant states. Diabetes Care. 2006;29(3):732-40. Does not include original data. [pmid: 16505541].
59 Bo S, Monge L, Macchetta C, et al. Prior gestational hyperglycemia: a long-term predictor of the metabolic syndrome. J Endocrinol Invest. 2004;27(7):629-35. Not evaluating people with gestational diabetes. [pmid: 15505985].
60 Bochner CJ, Medearis AL, Williams J, et al. Early third-trimester ultrasound screening in gestational diabetes to determine the risk of macrosomia and labor dystocia at term. Am J Obstet Gynecol. 1987;157(3):703-8. No appropriate comparison group for KQ1. [pmid: 3307427].
61 Bonomo M, Cetin I, Pisoni MP, et al. Flexible treatment of gestational diabetes modulated on ultrasound evaluation of intrauterine growth: a controlled randomized clinical trial. Diabetes Metab. 2004;30(3):237-44. Does not have a comparison of interest. [pmid: 15223975].
62 Bonomo M, Mion E, Greco P, et al. Maternal glycometabolic optimization and pregnancy outcome in gestational diabetes mellitus. Diabetes Nutr Metab Clin Exp. 1998;11(1):1-7. Other.
63 Botta RM, Di Giovanni BM, Cammilleri F, et al. Predictive factors for insulin treatment in women with diagnosis of gestational diabetes. Ann Ist Super Sanita. 1997;33(3):403-6. Does not have a comparison of interest. [pmid: 9542271].
64 Bracero LA, Cassidy S, Byrne DW. Effect of gender on perinatal outcome in pregnancies complicated by diabetes. Gynecol Obstet Invest. 1996;41(1):10-14. Not evaluating people with gestational diabetes. [pmid: 8821877].
65 Brown FM, Wyckoff J, Rowan JA, et al. Metformin in pregnancy: its time has not yet come. Diabetes Care. 2006;29(2):485-6. Does not include original data. [pmid: 16443923].
66 Brown ZA, Mills JL, Metzger BE, et al. Early sonographic evaluation for fetal growth delay and congenital malformations in pregnancies complicated by insulin-requiring diabetes. Diabetes Care. 1992;15(5):613-619. Does not apply to a key question. [pmid: 1516479].
67 Brudenell JM. Delivering the baby of the diabetic mother. J R Soc Med. 1978;71(3):207-211. No appropriate comparison group for KQ1. [pmid: 633278].
68 Buchanan TA. Birth defects in diabetic pregnancies: where do we go from here?. Eur J Endocrinol. 1996;134(4):395-7. Does not include original data. [pmid: 8640282].
69 Buchanan TA, Kjos SL. Diabetes and pregnancy. Curr Ther Endocrinol Metab. 1994;5:278-83. Does not include original data. [pmid: 7704732].
70 Buchanan TA, Kjos SL, Montoro MN, et al. Use of fetal ultrasound to select metabolic therapy for pregnancies complicated by mild gestational diabetes. Diabetes Care. 1994;17(4):275-83. Diagnosis of gestational diabetes not confirmed. [pmid: 8026282].
71 Buchanan TA, Xiang A, Kjos SL, et al. Gestational diabetes: Antepartum characteristics predict postpartum glucose intolerance and type 2 diabetes in Latino women. Diabetes. 1998;47(8):1302-1310. Other. [pmid: 9703332].
72 Burkart W, Hanker JP, Schneider HPG. Complications and fetal outcome in diabetic pregnancy. Intensified conventional versus insulin pump therapy. Gynecol Obstet Invest. 1988;26(2):104-112. Not evaluating people with gestational diabetes. [pmid: 3065158].
73 Byrne MM, Sturis J, O'Meara NM, et al. Insulin secretion in insulin-resistant women with a history of gestational diabetes. Metabolism. 1995;44(8):1067-73. Other. [pmid: 7637649].
74 Camm J. Babies at risk from mothers' diabetes. RCM Midwives. 2005;8(11):442. Does not include original data. [pmid: 16312117].
75 Carpenter MW, Coustan DR, Widness JA, et al. Postpartum testing for antecedent gestational diabetes. Am J Obstet Gynecol. 1988;159(5):1128-31. Other. [pmid: 3189447].
76 Carr DB, Utzschneider KM, Hull RL, et al. Gestational diabetes mellitus increases the risk of cardiovascular disease in women with a family history of type 2 diabetes. Diabetes Care. 2006;29(9):2078-83. Other. [pmid: 16936156].
77 Carrington ER. Diabetes in pregnancy. Clin Obstet Gynecol. 1973;16(1):28-46. Does not include original data. [pmid: 4575532].
78 Caruso A, Lanzone A, Bianchi V, et al. Continuous subcutaneous insulin infusion (CSII) in pregnant diabetic patients. Prenat Diagn. 1987;7(1):41-50. Other. [pmid: 3823006].
79 Cassano F. The treatment of diabetics and prediabetics in pregnancy. Folia Endocrinol. 1966;19(1):1-6. Not evaluating people with gestational diabetes. [pmid: 5953701].
80 Catalano PM, Bernstein IM, Wolfe RR, et al. Subclinical abnormalities of glucose metabolism in subjects with previous gestational diabetes. Am J Obstet Gynecol. 1986;155(6):1255-62. Other. [pmid: 3538877].
81 Catalano PM, Vargo KM, Bernstein IM, et al. Incidence and risk factors associated with abnormal postpartum glucose tolerance in women with gestational diabetes. Am J Obstet Gynecol. 1991;165(4 Pt 1):914-9. Other. [pmid: 1951553].
82 Cheung NW, Oats JJ, McIntyre HD. Australian carbohydrate intolerance study in pregnant women: implications for the management of gestational diabetes. Aust N Z J Obstet Gynaecol. 2005;45(6):484-5. Does not include original data. [pmid: 16401212].
83 Chin RK. Hypertensive disorders of pregnancy and gestational diabetes mellitus in mature gravidae. Br J Clin Pract. 1990;44(12):560-1. Does not apply to a key question. [pmid: 2102143].
84 Chollet MB, Pettitt DJ. Treatment of gestational diabetes mellitus. Clinical Diabetes. 2006;24(1):35-36. No appropriate comparison group for KQ1.
85 Chung JH, Voss KJ, Caughey AB, et al. Role of patient education level in predicting macrosomia among women with gestational diabetes mellitus. J Perinatol. 2006;26(6):328-32. Diagnosis of gestational diabetes not confirmed. [pmid: 16642026].
86 Cocilovo G, Tomasi F, Guerra S, et al. Risk factors associated with persistence of glucose intolerance one year after gestational diabetes. Diabete Metab. 1990;16(3):187-91. Other. [pmid: 2210012].
87 Coetzee EJ, Jackson WP. Diabetes newly diagnosed during pregnancy: A 4-year study at Groote Schuur Hospital. S Afr Med J. 1979;56(12):467-75. Diagnosis of gestational diabetes not confirmed. [pmid: 121638].
88 Cohen AM, Schenker JG. The effect of insulin treatment on fetal mortality and congenital malformations in diabetic pregnant women. Adv Exp Med Biol. 1972;27(-):377-381. No appropriate comparison group for KQ1. [pmid: 4680131].
89 Cole HS, Bilder JH, Camerini-Davalos RA, et al. Glucose tolerance, insulin and growth hormone in infants of gestational diabetic mothers. Pediatrics. 1970;45(3):394-403. Does not apply to a key question. [pmid: 5442913].
90 Collins VR, Dowse GK, Zimmet PZ. Evidence against association between parity and NIDDM from five population groups. Diabetes Care. 1991;14(11):975-81. Not evaluating people with gestational diabetes. [pmid: 1797511].
91 Comtois R, Seguin MC, Aris-Jilwan N, et al. Comparison of obese and non-obese patients with gestational diabetes. Int J Obes Relat Metab Disord. 1993;17(10):605-8. Does not apply to a key question. [pmid: 8242130].
92 Corcoy R, Garcia-Patterson A, Albareda M, et al. Poor performance of American Diabetes Association criteria in women with gestational diabetes. Diabetes Care. 2000;23(3):430-1. Does not include original data. [pmid: 10868888].
93 Coustan DR. Maternal insulin to lower the risk of fetal macrosomia in diabetic pregnancy. Clin Obstet Gynecol. 1991;34(2):288-295. Does not include original data. [pmid: 1868636].
94 Coustan DR, Carpenter MW. Detection and treatment of gestational diabetes. Clin Obstet Gynecol. 1985;28(3):507-15. Does not include original data. [pmid: 3902304].
95 Coustan DR, Imarah J. Prophylactic insulin treatment of gestational diabetes reduces the incidence of macrosomia, operative delivery, and birth trauma. Am J Obstet Gynecol. 1984;150(7):836-42. Does not have a comparison of interest. [pmid: 6391174].
96 Coustan DR, Lewis SB. Insulin therapy for gestational diabetes. Obstet Gynecol. 1978;51(3):306-10. Does not have a comparison of interest. [pmid: 628532].
97 Coustan DR, Carpenter MW, O'Sullivan PS, et al. Gestational diabetes: predictors of subsequent disordered glucose metabolism. Am J Obstet Gynecol. 1993;168(4):1139-44. discussion 1144–5. Does not evaluate risk factors for type 2 diabetes. [pmid: 8475959].
98 Coustan DR, Reece EA, Sherwin RS. A randomized clinical trial of the insulin pump vs intensive conventional therapy in diabetic pregnancies. J Am Med Assoc. 1986;255(5):631-636. Not evaluating people with gestational diabetes.
99 Crowther CA, Hiller JE, Moss JR, et al. Effect of treatment of gestational diabetes mellitus on pregnancy outcomes. N Engl J Med. 2005;352(24):2477-86. No appropriate comparison group for KQ1. [pmid: 15951574].
100 Cuasay LC, Lee ES, Orlander PP, et al. Prevalence and determinants of type 2 diabetes among Filipino-Americans in the Houston, Texas metropolitan statistical area. Diabetes Care. 2001;24(12):2054-8. Does not include original data. [pmid: 11723082].
101 Cundy T, Ducker L, Wrathall K, et al. Agreement between old and new diagnostic criteria in postpartum testing of women with gestational diabetes. Diabetes Care. 1998;21(9):1579-80. Does not include original data. [pmid: 9727922].
102 Cundy T, Gamble G, Manuel A, et al. Determinants of birth-weight in women with established and gestational diabetes. Aust N Z J Obstet Gynaecol. 1993;33(3):249-54. Does not apply to a key question. [pmid: 8304885].
103 Cypryk K, Sobczak M, Pertynska-Marczewska M, et al. Pregnancy complications and perinatal outcome in diabetic women treated with Humalog (insulin lispro) or regular human insulin during pregnancy. Med Sci Monit. 2004;10(2):PI29-PI32. Not evaluating people with gestational diabetes. [pmid: 14737056].
104 Czeszynska MB, Ronin-Walknowska E. Maternal glycemic control, cord blood insulin and erythropoietin levels in relation to indications for Cesarean section in diabetic pregnancy. Prenat Neonatal Med. 2000;5(4):236-242. Not evaluating people with gestational diabetes.
105 Dalfra MG, Lapolla A, Masin M, et al. Antepartum and early postpartum predictors of type 2 diabetes development in women with gestational diabetes mellitus. Diabetes Metab. 2001;27(6):675-80. Does not report a relative measure. [pmid: 11852376].
106 Damm P. Gestational diabetes mellitus and subsequent development of overt diabetes mellitus. Dan Med Bull. 1998;45(5):495-509. Does not include original data. [pmid: 9850811].
107 Damm P, Kuhl C, Hornnes P, et al. A longitudinal study of plasma insulin and glucagon in women with previous gestational diabetes. Diabetes Care. 1995;18(5):654-65. Diagnosis of gestational diabetes not confirmed. [pmid: 8586003].
108 Dandolu V. Increasis in the rate of shoulder dystocia. J Matern Fetal Neonatal Med. 2006;19(5):315. author reply 315–6. Does not include original data. [pmid: 16753774].
109 Dandona P, Besterman HS, Freedman DB. Continuous subcutaneous infusion of insulin (CSII) during pregnancy and fetal size. Pract Diabetes. 1986;3(1):33-35. Not evaluating people with gestational diabetes.
110 Dandrow RV, O'Sullivan JB. Obstetric hazards of gestational diabetes. Am J Obstet Gynecol. 1966;96(8):1144-7. Does not apply to a key question. [pmid: 5333231].
111 Davis CL, Gutt M, Llabre MM, et al. History of gestational diabetes, insulin resistance and coronary risk. J Diabetes Complications. 1999;13(4):216-23. Other. [pmid: 10616862].
112 De Muylder X. Perinatal complications of gestational diabetes: the influence of the timing of the diagnosis. Eur J Obstet Gynecol Reprod Biol. 1984;18(12):35-42. Does not have a comparison of interest. [pmid: 6500149].
113 De Veciana M, Major CA, Morgan MA, et al. Postprandial vs preprandial blood glucose monitoring in women with gestational diabetes mellitus requiring insulin therapy. New England Journal of Medicine. 1995;333:1237-1241. No appropriate comparison group for KQ1. [pmid: 7565999].
114 Delaney JJ, Ptacek J. Three decades of experience with diabetic pregnancies. Am J Obstet Gynecol. 1970;106(4):550-556. No appropriate comparison group for KQ1. [pmid: 5412848].
115 Delpapa EH, Mueller-Heubach E. Pregnancy outcome following ultrasound diagnosis of macrosomia. Obstet Gynecol. 1991;78(3 Pt 1):340-3. Not evaluating people with gestational diabetes. [pmid: 1876361].
116 Di Cianni G, Benzi L, Bottone P, et al. Neonatal outcome and obstetric complications in women with gestational diabetes: effects of maternal body mass index. Int J Obes Relat Metab Disord. 1996;20(5):445-9. Does not apply to a key question. [pmid: 8696423].
117 Di Rado A. Insulating against resistance: recent insights into the risk factors predisposing people to type 2 diabetes are leading researchers to new prevention and treatment strategies. USC Health. 2001;9(1):10-13. Does not include original data.
118 Diamond MP, Salyer SL, Boehm FH, et al. Congenital anomalies in offspring of insulin-dependent diabetic mothers. Diabetes Educ. 1986;12(3):272-276. Not evaluating people with gestational diabetes. [pmid: 3527622].
119 Dixon G. Management of diabetes in pregnancy. Midwife Health Visit 1974;10(10):304–7, 310–2. Does not apply to a key question
120 Dolger H, Bookman JJ, Nechemias C. The Management Of Diabetes In Pregnancy. J Mt Sinai Hosp N Y. 1963;30:479-90. Does not include a medication of interest for KQ1. [pmid: 14084154].
121 Dong ZG, Beischer NA, Wein P, et al. Value of early glucose tolerance testing in women who had gestational diabetes in their previous pregnancy. Aust N Z J Obstet Gynaecol. 1993;33(4):350-7. Diagnosis of gestational diabetes not confirmed. [pmid: 8179539].
122 Dooley SL, Metzger BE, Cho NH. Gestational diabetes mellitus. Influence of race on disease prevalence and perinatal outcome in a U.S. population. Diabetes. 1991;40(Suppl 2):25-9. Does not apply to a key question. [pmid: 1748260].
123 Dorner T, Rathmanner T, Lechleitner M, et al. Public health aspects of diabetes mellitus—epidemiology, prevention strategies, policy implications: the first Austrian diabetes report. Wien Klin Wochenschr. 2006;118(1718):513-9. Does not include original data. [pmid: 17009062].
124 Dornhorst A. A comparison of glyburide and insulin in women with gestational diabetes mellitus. Diabet Med 2001;Suppl 3:12–4. Does not include original data
125 Dornhorst A, Frost G. The potential for dietary intervention postpartum in women with gestational diabetes. Diabetes Care. 1997;20(11):1635-7. Does not apply to a key question. [pmid: 9353597].
126 Dornhorst A, Rossi M. Risk and prevention of type 2 diabetes in women with gestational diabetes. Diabetes Care. 1998;21(Suppl 2):B43-9. Does not include original data. [pmid: 9704226].
127 Dornhorst A, Bailey PC, Anyaoku V, et al. Abnormalities of glucose tolerance following gestational diabetes. Q J Med. 1990;77(284):1219-28. Diagnosis of gestational diabetes not confirmed. [pmid: 2290918].
128 Drexel H, Bichler A, Sailer S, et al. Prevention of perinatal morbidity by tight metabolic control in gestational diabetes mellitus. Diabetes Care. 1988;11(10):761-8. Does not have a comparison of interest. [pmid: 3073066].
129 Driscoll JJ, Gillespie L. Obstetrical Considerations In Diabetes In Pregnancy. Med Clin North Am. 1965;49:1025-34. Does not include original data. [pmid: 14300322].
130 Dunne F. Gestational diabetes. Diabet Med. 2004;21(Suppl 3):6-8. Does not include original data. [pmid: 15089778].
131 Durnwald C, Landon MB. Glyburide: the new alternative for treating gestational diabetes?. Am J Obstet Gynecol. 2005;193(1):1-2. Does not include original data. [pmid: 16021049].
132 Dutta R, Kulenthran A, Sivanesaratnam V, et al. Management of pregnancy complicated by diabetes mellitus: experience at the University Hospital, Kuala Lumpur. Asia Oceania J Obstet Gynaecol. 1988;14(3):307-311. Other. [pmid: 3052393].
133 Ecker JL, Greenberg JA, Norwitz ER, et al. Birth weight as a predictor of brachial plexus injury. Obstet Gynecol. 1997;89(5 Pt 1):643-7. Not evaluating people with gestational diabetes. [pmid: 9166293].
134 Ecker JL, Mascola MA, Riley LE. Gestational diabetes. N Engl J Med. 2000;342(12):896-7. Does not include original data. [pmid: 10733380].
135 Efendic S, Hanson U, Persson B, et al. Glucose tolerance, insulin release, and insulin sensitivity in normal-weight women with previous gestational diabetes mellitus. Diabetes. 1987;36(4):413-9. Other. [pmid: 3545944].
136 Egeland GM, Skjaerven R, Irgens LM. Birth characteristics of women who develop gestational diabetes: population based study. BMJ. 2000;321(7260):546-7. Does not apply to a key question. [pmid: 10968815].
137 Ehrenberg HM, Durnwald CP, Catalano P, et al. The influence of obesity and diabetes on the risk of cesarean delivery. Am J Obstet Gynecol. 2004;191(3):969-74. Not evaluating people with gestational diabetes. [pmid: 15467574].
138 Ehrenberg HM, Mercer BM, Catalano PM. The influence of obesity and diabetes on the prevalence of macrosomia. Am J Obstet Gynecol. 2004;191(3):964-8. Does not have a comparison of interest. [pmid: 15467573].
139 el-Shafei AM, Bashmi YA, Beischer NA, et al. Incidence and severity of gestational diabetes in Bahrain and Australia. Aust N Z J Obstet Gynaecol. 1989;29(3 Pt 1):204-8. Diagnosis of gestational diabetes not confirmed. [pmid: 2604648].
140 Elliott JP, Garite TJ, Freeman RK. Ultrasonic prediction of fetal macrosomia in diabetic patients. Obstetrics and Gynecology: Obstet Gynecol. 1982;60(2):159-162. Not evaluating people with gestational diabetes. [pmid: 7155475].
141 Elliott P. A review of the significance of gestational diabetes. Aust N Z J Obstet Gynaecol. 1978;18(1):21-7. Does not apply to a key question. [pmid: 278583].
142 Fallucca F, Di Mario U, Gargiulo P, et al. Humoral immunity in diabetic pregnancy: interrelationships with maternal/neonatal complications and maternal metabolic control. Diabete Metab. 1985;11(6):387-95. Diagnosis of gestational diabetes not confirmed. [pmid: 3910490].
143 Fan ZT, Yang HX, Gao XL, et al. Pregnancy outcome in gestational diabetes. Int J Gynaecol Obstet. 2006;94(1):12-6. Does not have a comparison of interest. [pmid: 16733056].
144 Farrag OA. Prospective study of 3 metabolic regimens in pregnant diabetics. Aust N Z J Obstet Gynaecol. 1987;27(1):6-9. Not evaluating people with gestational diabetes. [pmid: 3304264].
145 Farrell J, Forrest JM, Storey GN, et al. Gestational diabetes—infant malformations and subsequent maternal glucose tolerance. Aust N Z J Obstet Gynaecol. 1986;26(1):11-6. No appropriate comparison group for KQ1. [pmid: 3524546].
146 Farrell T, Fraser R, Chan K. Ultrasonic fetal weight estimation in women with pregnancy complicated by diabetes. Acta Obstet Gynecol Scand. 2004;83(11):1065-6. Not evaluating people with gestational diabetes. [pmid: 15488123].
147 Feinstein U, Sheiner E, Levy A, et al. Risk factors for arrest of descent during the second stage of labor. Int J Gynaecol Obstet. 2002;77(1):7-14. Does not have a comparison of interest. [pmid: 11929650].
148 Feldberg D, Dicker D, Samuel N, et al. Intrapartum management of insulin-dependent diabetes mellitus (IDDM) gestants. A comparative study of constant intravenous insulin infusion and continuous subcutaneous insulin infusion pump (CSIIP). Acta Obstet Gynecol Scand. 1988;67(4):333-338. Not evaluating people with gestational diabetes. [pmid: 3051881].
149 Fines Verlee, Moore Thomas, Castle Shannon. A comparison of glyburide and insulin treatment in gestational diabetes mellitus on infant birth weight and adiposity: SMFM abstracts. American Journal of Obstetrics and Gynecology. 2003;189(6, Supplement 1):S108. Does not include original data.
150 Fisher PM, Sutherland HW, Bewsher PD. The insulin response to glucose infusion in gestational diabetes. Diabetologia. 1980;19(1):10-4. Does not apply to a key question. [pmid: 6993262].
151 Fitz-Patrick D. Autoimmunity in “type 2” and gestational diabetes mellitus. Endocr Pract. 2001;7(5):407-8. Does not apply to a key question. [pmid: 11585380].
152 Forbes S, Moonan M, Robinson S, et al. Impaired circulating glucagon-like peptide-1 response to oral glucose in women with previous gestational diabetes. Clin Endocrinol (Oxf). 2005;62(1):51-5. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 15638870].
153 Foster-Powell KA, Cheung NW. Recurrence of gestational diabetes. Aust N Z J Obstet Gynaecol. 1998;38(4):384-7. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 9890214].
154 Fraser R. Diabetic control in pregnancy and intrauterine growth of the fetus. Br J Obstet Gynaecol. 1995;102(4):275-7. Does not include original data. [pmid: 7612507].
155 Fraser R. Diabetes in pregnancy. Arch Dis Child Fetal Neonatal Ed. 1994;71(3):F224-30. Does not include original data. [pmid: 7820724].
156 Fraser R. Gestational diabetes: After the ACHOIS trial. Diabetic Med. 2006;23(SUPPL. 1):8-11. Does not include original data. [pmid: 16483258].
157 Freilich TH. Management of the pregnant woman with diabetes. J Am Osteopath Assoc. 1970;69(12):1221-1224. Case report or case series of less than 50 cases. [pmid: 5202469].
158 Friedlander AH, Chaudhuri G, Altman L. A past medical history of gestational diabetes: its medical significance and its dental implications. Oral Surg Oral Med Oral Pathol Oral Radiol Endod. 2007;103(2):157-63. Does not include original data. [pmid: 17234528].
159 Friedman JE, Ishizuka T, Shao J, et al. Impaired glucose transport and insulin receptor tyrosine phosphorylation in skeletal muscle from obese women with gestational diabetes. Diabetes. 99;48(9):1807-14. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 10480612].
160 Gabbe SG, Graves CR. Management of diabetes mellitus complicating pregnancy. Obstetrics Gynecology. 2003;102(4):857-868. Does not include original data. [pmid: 14551019].
161 Gaillard TR, Schuster DP, Bossetti BM, et al. Do sociodemographics and economic status predict risks for type II diabetes in African Americans?. Diabetes Educ. 1997;23(3):294-300. Not evaluating people with gestational diabetes. [pmid: 9257620].
162 Gamson K, Chia S, Jovanovic L. The safety and efficacy of insulin analogs in pregnancy. J Matern-Fetal Neonatal Med. 2004;15(1):26-34. Does not include original data. [pmid: 15101608].
163 Garcia-Patterson A, Martin E, Ubeda J, et al. Evaluation of light exercise in the treatment of gestational diabetes. Diabetes Care. 2001;24(11):2006-7. Does not apply to a key question. [pmid: 11679479].
164 Gasic S, Winzer Ch, Bayerle-Eder M, et al. Impaired cardiac autonomic function in women with prior gestational diabetes mellitus. Eur J Clin Invest. 2007;37(1):42-7. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 17181566].
165 Gillmer M D, Persson B. Metabolism during normal and diabetic pregnancy and its effect on neonatal outcome. Ciba Found Symp 1978;(63):93–126. No appropriate comparison group for KQ1
166 Gillmer MD, Maresh M, Beard RW, et al. Low energy diets in the treatment of gestational diabetes. Acta Endocrinol Suppl (Copenh). 1986;277:44-9. Diagnosis of gestational diabetes not confirmed. [pmid: 3532669].
167 Goetzl L, Wilkins I. Glyburide compared to insulin for the treatment of gestational diabetes mellitus: a cost analysis (Provisional record). Journal of Perinatology. 2002;22(5):403-406. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 12082477].
168 Gojnic M, Pervulov M, Petkovic S, et al. Acceleration of fetal maturation by oxytocin-produced uterine contraction in pregnancies complicated with gestational diabetes mellitus: a preliminary report. J Matern Fetal Neonatal Med. 2004;16(2):111-4. Case report or case series of less than 50 cases. [pmid: 15512721].
169 Goldberg JD, Franklin B, Lasser D, et al. Gestational diabetes: impact of home glucose monitoring on neonatal birth weight. Am J Obstet Gynecol. 1986;154(3):546-50. Does not include a medication of interest for KQ1. [pmid: 3513584].
170 Goldkrand JW, Lin JY. Large for gestational age: dilemma of the infant of the diabetic mother. J Perinatol. 1987;7(4):282-7. Not evaluating people with gestational diabetes. [pmid: 3505263].
171 Goldman M, Kitzmiller JL, Abrams B, et al. Obstetric complications with GDM. Effects of maternal weight. Diabetes. 1991;40(Suppl 2):79-82. No appropriate comparison group for KQ1. [pmid: 1748271].
172 Gonen R, Bader D, Ajami M. Effects of a policy of elective cesarean delivery in cases of suspected fetal macrosomia on the incidence of brachial plexus injury and the rate of cesarean delivery. Am J Obstet Gynecol. 2000;183(5):1296-300. Not evaluating people with gestational diabetes. [pmid: 11084580].
173 Gonzalez JL. Management of diabetes in pregnancy. Clinical Obstetrics Gynecology. 2002;45(1):165-171. Does not include original data. [pmid: 11862067].
174 Gonzalez S, Mlinarevich N, Michalski-Rimington AN, et al. The Latina gestational diabetes mellitus pilot study: Baseline data. Hisp Healthc Int. 2005;3(1):21-26. Does not apply to a key question.
175 Grandis AS, Morris MA, Litton JC. Gestational diabetes: maternal response to diet and insulin therapy as reflected by glycosylated hemoglobin concentration. Am J Obstet Gynecol. 1987;157(5):1118-21. Does not have a comparison of interest. [pmid: 3318463].
176 Grasso S, Roversi GD. Oversized infant of diabetic mother: its cause and prevention. J Perinat Med. 1987;15(1):73-82. Does not apply to a key question. [pmid: 3295177].
177 Grasso S, Roversi GD. Oversized infants of diabetic mothers: Cause and prevention. J Perinat Med. 1987;15(1):73-82. Does not include a medication of interest for KQ1. [pmid: 3295177].
178 Greene MF. Oral hypoglycemic drugs for gestational diabetes. N Engl J Med. 2000;343(16):1178-9. Does not include original data. [pmid: 11036125].
179 Greene MF, Solomon CG. Gestational diabetes mellitus — time to treat. N Engl J Med. 2005;352(24):2544-6. Does not include original data. [pmid: 15951575].
180 Gruendhammer M, Brezinka C, Lechleitner M. The number of abnormal plasma glucose values in the oral glucose tolerance test and the fetomaternal outcome of pregnancy. Eur J Obstet Gynecol Reprod Biol. 2003;108(2):131-6. No appropriate comparison group for KQ1. [pmid: 12781399].
181 Gyves MT, Rodman HM, Little AB, et al. A modern approach to management of pregnant diabetics: a two-year analysis of perinatal outcomes. Am J Obstet Gynecol. 1977;128(6):606-16. Does not apply to a key question. [pmid: 879221].
182 Gyves MT, Schulman PK, Merkatz IR. Results of individualized intervention in gestational diabetes. Diabetes Care. 1980;3(3):495-6. Does not apply to a key question. [pmid: 7389567].
183 Hadden DR, Alexander A, McCance DR, et al. Obstetric and diabetic care for pregnancy in diabetic women: 10 Years outcome analysis, 1985-1995. Diabetic Med. 2001;18(7):546-553. Does not include original data. [pmid: 11553183].
184 Hamada T, Yoshimatsu K, Ooshima T, et al. The influence of age on glucose tolerance during pregnancy. Kurume Med J. 1985;32(4):279-283. Not evaluating people with gestational diabetes. [pmid: 3915761].
185 Hanley AJG, Harris SB, Zinman B. Application of the revised American Diabetes Association criteria for the diagnosis of diabetes in a Canadian native population [4]. Diabetes Care: Diabetes Care. 1998;21(5):870-871. Does not include original data. [pmid: 9589260].
186 Hanson U, Persson B, Stangenberg M. Factors influencing neonatal morbidity in diabetic pregnancy. Diabetes Res. 1986;3(2):71-76. Not evaluating people with gestational diabetes. [pmid: 3698482].
187 Hanson U, Persson B, Hartling SG, et al. Increased molar proinsulin-to-insulin ratio in women with previous gestational diabetes does not predict later impairment of glucose tolerance. Diabetes Care. 1996;19(1):17-20. Other. [pmid: 8720527].
188 Harnett M, Datta S. Diabetes in pregnancy. Seminars in Anesthesia, Perioperative Medicine Pain. 2000;19(3):188-195. Does not include original data.
189 Harris JL. Diabetes mellitus in pregnancy. West J Med. 1992;156(6):647-8. Does not include original data. [pmid: 1615657].
190 Hawthorne G, Irgens LM, Lie RT. Outcome of pregnancy in diabetic women in northeast England and in Norway, 1994-7. BMJ: British Medical Journal. 2000-;321(7263):730-731. Not evaluating people with gestational diabetes. [pmid: 10999902].
191 Hedderson MM, Ferrara A, Sacks DA. Gestational diabetes mellitus and lesser degrees of pregnancy hyperglycemia: association with increased risk of spontaneous preterm birth. Obstet Gynecol. 2003;102(4):850-6. Does not apply to a key question. [pmid: 14551018].
192 Hellmuth E, Damm P, Molsted-Pedersen L. Oral hypoglycaemic agents in 118 diabetic pregnancies. Diabet Med. 2000;17(7):507-11. Diagnosis of gestational diabetes not confirmed. [pmid: 10972579].
193 Henry OA, Beischer NA. Long-term implications of gestational diabetes for the mother. Baillieres Clin Obstet Gynaecol. 1991;5(2):461-83. Does not report a relative measure. [pmid: 1954723].
194 Henry OA, Beischer NA, Sheedy MT, et al. Gestational diabetes and follow-up among immigrant Vietnam-born women. Aust N Z J Obstet Gynaecol. 1993;33(2):109-14. Diagnosis of gestational diabetes not confirmed. [pmid: 8216103].
195 Herbison P, Wilson D. Intensified versus conventional management of gestational diabetes. Am J Obstet Gynecol. 1995;172(5):1642-3. Does not include original data. [pmid: 7755089].
196 Herbison P, Wilson D. Implications of gestational diabetes for the future health of the mother. Br J Obstet Gynaecol. 1995;102(5):427-8. Does not include original data. [pmid: 7677864].
197 Higham R. Caesarean section: an analysis of 200 cases performed in a district hospital. Med J Aust. 1967;2(11):505-506. Not evaluating people with gestational diabetes. [pmid: 6070971].
198 Hod M, Shafrir E. Oral hypoglycemic agents as an alternative therapy for gestational diabetes. ISR J MED SCI. 1995;31(10):640-643. Does not include original data. [pmid: 7591693].
199 Hod M, Bar J, Peled Y, et al. Antepartum management protocol. Timing and mode of delivery in gestational diabetes. Diabetes Care. 1998;21(Suppl 2):B113-7. Other. [pmid: 9704237].
200 Hod M, Merlob P, Friedman S, et al. Gestational diabetes mellitus. A survey of perinatal complications in the 1980s. Diabetes. 1991;40(Suppl 2):74-8. Does not have a comparison of interest. [pmid: 1748270].
201 Hod M, Rabinerson D, Kaplan B, et al. Perinatal complications following gestational diabetes mellitus how ‘sweet’ is ill?. Acta Obstet Gynecol Scand. 1996;75(9):809-15. Does not have a comparison of interest. [pmid: 8931504].
202 Hoet JJ. Effect of intervention in gestational diabetes. Diabetes Care. 1980;3(3):497-8. Does not include original data. [pmid: 6993165].
203 Holt TA. Long term follow up of women who have had gestational diabetes. Br J Gen Pract. 1992;42(362):354-5. Does not include original data. [pmid: 1457167].
204 Homko CJ, Sivan E, Nyirjesy P, et al. The interrelationship between ethnicity and gestational diabetes in fetal macrosomia. Diabetes Care. 1995;18(11):1442-5. No appropriate comparison group for KQ1. [pmid: 8722067].
205 Horger EO 3rd, Kellett WW 3rd, Williamson HO. Diabetes in pregnancy. A review of 143 cases. Obstet Gynecol. 1967;30(1):46-53. Does not apply to a key question. [pmid: 4961248].
206 Horrigan TJ. Physicians who induce labor for fetal macrosomia do not reduce cesarean delivery rates. J Perinatol. 2001;21(2):93-6. Not evaluating people with gestational diabetes. [pmid: 11324367].
207 Hoshi J, Nishida H, Takahashi N, et al. Perinatal morbidity of infants of diabetic mothers. Acta Paediatr Jpn Overs Ed. 1991;33(2):159-165. Not evaluating people with gestational diabetes.
208 Hu FB, Manson JE, Stampfer MJ, et al. Diet, lifestyle, and the risk of type 2 diabetes mellitus in women. N Engl J Med. 2001;345(11):790-7. Not evaluating people with gestational diabetes. [pmid: 11556298].
209 Huddle KR, Myer IG, Diamond TH, et al. Diabetes in pregnancy. The use of home blood glucose monitoring and intensive monitoring to ensure favourable perinatal outcome. S Afr Med J. 1987;71(7):429-31. Does not apply to a key question. [pmid: 3551132].
210 Huddleston J F. Diagnosis and management of diabetes in pregnancy. J Med Assoc State Ala 1980;50(1):31–3, 37. Does not include original data
211 Hunger-Dathe W, Mosebach N, Samann A, et al. Prevalence of impaired glucose tolerance 6 years after gestational diabetes. Exp Clin Endocrinol Diabetes. 2006;114(1):11-7. Diagnosis of gestational diabetes not confirmed. [pmid: 16450311].
212 Hunger-Dathe W, Volk K, Braun A, et al. Perinatal morbidity in women with undiagnosed gestational diabetes in northern thuringia in Germany. Exp Clin Endocrinol Diabetes. 2005;113(3):160-6. Does not apply to a key question. [pmid: 15789275].
213 Hunter DJ. Gestational diabetes. Aust N Z J Obstet Gynaecol. 1987;27(2):170-1. Does not include original data. [pmid: 3675447].
214 Ismajovich B, Mashiach S, Zukut H, et al. The effects of insulin of fetal development in “gestational diabetes”. Adv Exp Med Biol. 1972;27:383-9. Does not apply to a key question. [pmid: 4680132].
215 Isseh N, Takrouri MS. Metabolic management of diabetes during labor and delivery. Middle East J Anesthesiol. 1995;13(2):175-180. Does not include original data. [pmid: 7476739].
216 Jackson RF. Diabetes in pregnancy. J Indiana State Med Assoc. 1965;58(11):1228-34. Case report or case series of less than 50 cases. [pmid: 5834307].
217 Jacobson JD, Cousins L. A population-based study of maternal and perinatal outcome in patients with gestational diabetes. Am J Obstet Gynecol. 1989;161(4):981-6. Does not apply to a key question. [pmid: 2801849].
218 James WH. Gestational diabetes, birth weight, sex ratio, and cesarian section. Diabetes Care. 2001;24(11):2018-9. Does not apply to a key question. [pmid: 11679495].
219 Jardim O, Sobral E, Branco EC, et al. Delivery in diabetic pregnancy. Ann Ist Super Sanita. 1997;33(3):329-332. Does not apply to a key question. [pmid: 9542257].
220 Jarvela IY, Juutinen J, Koskela P, et al. Gestational diabetes identifies women at risk for permanent type 1 and type 2 diabetes in fertile age: predictive role of autoantibodies. Diabetes Care. 2006;29(3):607-12. Does not report a relative measure. [pmid: 16505514].
221 Jawad F, Irshaduddin PK. Prevalence of gestational diabetes and pregnancy outcome in Pakistan. Eastern Mediterranean Health Journal. 1996;2(2):268-273. Does not apply to a key question.
222 Jensen DM, Sorensen B, Feilberg-Jorgensen N, et al. Maternal and perinatal outcomes in 143 Danish women with gestational diabetes mellitus and 143 controls with a similar risk profile. Diabet Med. 2000;17(4):281-6. Does not have a comparison of interest. [pmid: 10821294].
223 Johns K, Olynik C, Mase R, et al. Gestational diabetes mellitus outcome in 394 patients. J Obstet Gynaecol Can. 2006;28(2):122-7. No appropriate comparison group for KQ1. [pmid: 16643713].
224 Johnstone FD, Nasrat AA, Prescott RJ. The effect of established and gestational diabetes on pregnancy outcome. Br J Obstet Gynaecol. 1990;97(11):1009-15. Does not have a comparison of interest. [pmid: 2252867].
225 Joseph SE. Macrosomia and poor glycaemic control in diabetic pregnancy. Diabet Med. 1996;13(12):1072. Does not include original data. [pmid: 8973891].
226 Jovanovic-Peterson L, Peterson CM. Dietary manipulation as a primary treatment strategy for pregnancies complicated by diabetes. J Am Coll Nutr. 1990;9(4):320-325. Does not apply to a key question. [pmid: 2212389].
227 Jovanovic-Peterson L, Peterson CM. Turning point in the management of pregnancies complicated by diabetes: Normoglycemia with self blood glucose monitoring of diet and insulin dosing. Asaio Trans. 1990;36(4):799-804. Case report or case series of less than 50 cases. [pmid: 2268482].
228 Jovanovic-Peterson L, Bevier W, Peterson CM. The Santa Barbara County Health Care Services program: birth weight change concomitant with screening for and treatment of glucose-intolerance of pregnancy: a potential cost-effective intervention?. Am J Perinatol. 1997;14(4):221-8. Not evaluating people with gestational diabetes. [pmid: 9259932].
229 Kadiki OA, Reddy MR, Sahli MA, et al. Outcome of pregnant diabetic patients in Benghazi (Libya) from 1984 to 1991. Diabetes Res Clin Pract. 1993;21(1):39-42. Not evaluating people with gestational diabetes. [pmid: 8253020].
230 Kale SD, Yajnik CS, Kulkarni SR, et al. High risk of diabetes and metabolic syndrome in Indian women with gestational diabetes mellitus. Diabet Med. 2004;21(11):1257-8. Diagnosis of gestational diabetes not confirmed. [pmid: 15498096].
231 Karlsson K, Kjellmer I. The outcome of diabetic pregnancies in relation to the mother's blood sugar level. Am J Obstet Gynecol. 1972;112(2):213-220. No appropriate comparison group for KQ1. [pmid: 5008447].
232 Kaufmann RC, Schleyhahn FT, Huffman DG, et al. Gestational diabetes diagnostic criteria: long-term maternal follow-up. Am J Obstet Gynecol. 1995;172(2 Pt 1):621-5. Does not report a relative measure. [pmid: 7856695].
233 Kelly S. The use of a sliding scale insulin regime during the intrapartum period for women diagnosed with gestational diabetes. Does it prevent neonatal hypoglycaemia?. N2N: Nurse2Nurse. 2003;3(8):50-52. Other.
234 Kemball ML, McIver C, Milner RD, et al. Neonatal hypoglycaemia in infants of diabetic mothers given sulphonylurea drugs in pregnancy. Arch Dis Child. 1970;45(243):696-701. Case report or case series of less than 50 cases. [pmid: 5477685].
235 Kerenyi Z, Tabak AG, Stella P, et al. Association between socioeconomic factors and the metabolic syndrome in women with prior gestational diabetes mellitus. Diabetes Care. 2000;23(9):1444-5. Does not include original data. [pmid: 10977058].
236 Keshavarz M, Cheung NW, Babaee GR, et al. Gestational diabetes in Iran: incidence, risk factors and pregnancy outcomes. Diabetes Res Clin Pract. 2005;69(3):279-86. Does not apply to a key question. [pmid: 16098925].
237 Khan KS, Hashmi FA, Rizvi JH. Are non-diabetic women with abnormal glucose screening test at increased risk of pre-eclampsia, macrosomia and caesarian birth?. J Pak Med Assoc. 1995;45(7):176-9. Does not apply to a key question. [pmid: 8523639].
238 Khonjandi M, Tsai M, Tyson JE. Gestational diabetes: the dilemma of delivery. Obstet Gynecol. 1974;43(1):1-6. Does not apply to a key question. [pmid: 4587642].
239 Kinalski M, Sledziewski A, Telejko B, et al. Post-partum evaluation of amylin in lean patients with gestational diabetes mellitus. Acta Diabetol. 2004;41(1):1-4. Does not apply to a key question. [pmid: 15057546].
240 King KC, Adam PA, Clemente GA, et al. Infants of diabetic mothers: attenuated glucose uptake without hyperinsulinemia during continuous glucose infusion. Pediatrics. 1969;44(3):381-392. Does not include a medication of interest for KQ1. [pmid: 5809895].
241 Kirby RS. Diabetes and congenital malformations. Paediatr Perinat Epidemiol. 1996;10(4):469-76. Does not include original data. [pmid: 8931060].
242 Kivnick SG, Fachnie JD, Lee CY. Current management of pregnancy in the diabetic: a team approach. Henry Ford Hosp Med J. 1983;31(2):84-90. Does not include original data. [pmid: 6629836].
243 Kjos SL, Berkowitz K, Xiang A. Independent predictors of cesarean delivery in women with diabetes. J Matern Fetal Neonatal Med. 2004;15(1):61-67. Not evaluating people with gestational diabetes. [pmid: 15101614].
244 Kjos SL, Henry O, Lee RM, et al. The effect of lactation on glucose and lipid metabolism in women with recent gestational diabetes. Obstet Gynecol. 1993;82(3):451-5. Does not report a relative measure. [pmid: 8355952].
245 Kjos SL, Leung A, Henry OA, et al. Antepartum surveillance in diabetic pregnancies: predictors of fetal distress in labor. Am J Obstet Gynecol. 1995;173(5):1532-9. Does not have a comparison of interest. [pmid: 7503197].
246 Kjos SL, Schaefer-Graf U, Sardesi S, et al. A randomized controlled trial using glycemic plus fetal ultrasound parameters versus glycemic parameters to determine insulin therapy in gestational diabetes with fasting hyperglycemia. Diabetes Care. 2001;24(11):1904-10. Does not have a comparison of interest. [pmid: 11679455].
247 Kjos SL, Shoupe D, Douyan S, et al. Effect of low-dose oral contraceptives on carbohydrate and lipid metabolism in women with recent gestational diabetes: results of a controlled, randomized, prospective study. Am J Obstet Gynecol. 1990;163(6 Pt 1):1822-7. Does not report a relative measure. [pmid: 2256489].
248 Knopp RH, Magee MS, Raisys V, et al. Metabolic effects of hypocaloric diets in management of gestational diabetes. Diabetes. 1991;40(Suppl 2):165-71. Does not have a comparison of interest. [pmid: 1748251].
249 Knopp RH, Magee MS, Raisys V, et al. Hypocaloric diets and ketogenesis in the management of obese gestational diabetic women. J AM COLL NUTR. 1991;10(6):649-667. Does not include original data. [pmid: 1770194].
250 Ko GT, Chan JC, Cockram CS. Change of glycaemic status in Chinese subjects with impaired fasting glycaemia. Diabet Med. 2001;18(9):745-8. Not evaluating people with gestational diabetes. [pmid: 11606173].
251 Ko GT, Chan JC, Tsang LW, et al. Glucose intolerance and other cardiovascular risk factors in chinese women with a history of gestational diabetes mellitus. Aust N Z J Obstet Gynaecol. 1999;39(4):478-83. Diagnosis of gestational diabetes not confirmed. [pmid: 10687769].
252 Ko GT, Chan JC, Tsang LW, et al. Outcomes of screening for diabetes in high-risk Hong Kong Chinese subjects. Diabetes Care. 2000;23(9):1290-4. Not evaluating people with gestational diabetes. [pmid: 10977020].
253 Ko GT, Chan JC, Yeung VT, et al. Combined use of a fasting plasma glucose concentration and HbA1c or fructosamine predicts the likelihood of having diabetes in high-risk subjects. Diabetes Care. 1998;21(8):1221-5. Not evaluating people with gestational diabetes. [pmid: 9702423].
254 Kodama Y, Sameshima H, Ikenoue T. Regional population-based study on pregnancy outcomes in women with diabetes mellitus in Japan. J Obstet Gynaecol Res. 2007;33(1):45-48. No appropriate comparison group for KQ1. [pmid: 17212665].
255 Koivunen RM, Juutinen J, Vauhkonen I, et al. Metabolic and steroidogenic alterations related to increased frequency of polycystic ovaries in women with a history of gestational diabetes. J Clin Endocrinol Metab. 2001;86(6):2591-9. No relevant risk factor for KQ3. [pmid: 11397859].
256 Koren G. Glyburide is safe for gestational diabetes mellitus. Can. Pharm. J. 2005;138(6):67+74. Does not include original data
257 Kousta E, Cela E, Lawrence N, et al. The prevalence of polycystic ovaries in women with a history of gestational diabetes. Clin Endocrinol (Oxf). 2000;53(4):501-7. Other. [pmid: 11012576].
258 Kousta E, Efstathiadou Z, Lawrence NJ, et al. The impact of ethnicity on glucose regulation and the metabolic syndrome following gestational diabetes. Diabetologia. 2006;49(1):36-40. Other. [pmid: 16341688].
259 Kousta E, Lawrence NJ, Godsland IF, et al. Insulin resistance and beta-cell dysfunction in normoglycaemic European women with a history of gestational diabetes. Clin Endocrinol (Oxf). 2003;59(3):289-97. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 12919151].
260 Kraus P A. Re: Walsh E. Re: Gestational Diabetes. What happens postpartum? Aust N Z J Obstet Gynaecol 2004;44(6):589. Does not include original data
261 Kremer CJ, Duff P. Glyburide for the treatment of gestational diabetes. Am J Obstet Gynecol. 2004;190(5):1438-9. Other. [pmid: 15167862].
262 Kripke C. Intensive management of gestational diabetes. Am Fam Physician. 2004;70(5):866. Does not include original data. [pmid: 15368725].
263 Krishna U, Panjabi J, Purandare VN. Some criteria for induction of labour in diabetes, toxemia of pregnancy and Rh immunization. J Postgrad Med. 1972;18(1):21-26. Other. [pmid: 4669528].
264 Kuhl C, Moller-Jensen B, Saurbrey N, et al. Intensified insulin treatment in diabetic pregnancy. Diabetes Educ. 1984;10:60-63. Not evaluating people with gestational diabetes. [pmid: 6376037].
265 Kung AW, Ma JT, Wong VC, et al. Glucose and lipid metabolism with triphasic oral contraceptives in women with history of gestational diabetes. Contraception. 1987;35(3):257-69. Other. [pmid: 3111786].
266 Laird J, McFarland KF. Fasting blood glucose levels and initiation of insulin therapy in gestational diabetes. Endocr Pract. 1996;2(5):330-2. Does not include original data. [pmid: 15251512].
267 Lam KS, Li DF, Lauder IJ, et al. Prediction of persistent carbohydrate intolerance in patients with gestational diabetes. Diabetes Res Clin Pract. 1991;12(3):181-6. Other. [pmid: 1889347].
268 Landon MB, Gabbe SG. Antepartum fetal surveillance in gestational diabetes mellitus. Diabetes. 1985;34(Suppl 2):50-4. Diagnosis of gestational diabetes not confirmed. [pmid: 3888742].
269 Landon MB, Sonek J, Foy P, et al. Sonographic measurement of fetal humeral soft tissue thickness in pregnancy complicated by GDM. Diabetes. 1991;40(Suppl 2):66-70. Does not apply to a key question. [pmid: 1748268].
270 Langer O. Management of gestational diabetes: Pharmacologic treatment options and glycemic control. Endocrinol Metab Clin North Am. 2006;35(1):53-78. Does not include original data. [pmid: 16310642].
271 Langer O, Maulik D. Developing evidence-based medicine for managing diabetes in pregnancy. J Matern Fetal Neonatal Med. 2002;11(4):217. Does not include original data. [pmid: 12375673].
272 Langer O, Mazze R. The relationship between large-for-gestational-age infants and glycemic control in women with gestational diabetes. Am J Obstet Gynecol. 88;159(6):1478-83. Does not have a comparison of interest. [pmid: 3207126].
273 Langer O, Berkus MD, Huff RW, et al. Shoulder dystocia: should the fetus weighing greater than or equal to 4000 grams be delivered by cesarean section?. Am J Obstet Gynecol. 1991;165(4 Pt 1):831-7. Not evaluating people with gestational diabetes. [pmid: 1951539].
274 Langer O, Berkus M, Brustman L, et al. Rationale for insulin management in gestational diabetes mellitus. Diabetes. 1991;40(Suppl 2):186-90. Does not have a comparison of interest. [pmid: 1748257].
275 Langer O, Conway DL, Berkus MD. Glyburide was as safe and effective as insulin in gestational diabetes. Evid-Based Med. 2001;6(3):79. Does not include original data.
276 Langer O, Levy J, Brustman L, et al. Glycemic control in gestational diabetes mellitus—how tight is tight enough: small for gestational age versus large for gestational age?. Am J Obstet Gynecol. 1989;161(3):646-53. No appropriate comparison group for KQ1. [pmid: 2782347].
277 Langer O, Rodriguez DA, Xenakis EM, et al. Intensified versus conventional management of gestational diabetes. Am J Obstet Gynecol. 1994;170(4):1036-46. discussion 1046–7. Does not have a comparison of interest. [pmid: 8166187].
278 Langer O, Yogev Y, Most O, et al. Gestational diabetes: the consequences of not treating. Am J Obstet Gynecol. 2005;192(4):989-97. Does not apply to a key question. [pmid: 15846171].
279 Langer O, Yogev Y, Xenakis EM, et al. Overweight and obese in gestational diabetes: the impact on pregnancy outcome. Am J Obstet Gynecol. 2005;192(6):1768-76. Does not have a comparison of interest. [pmid: 15970805].
280 Lao TT, Ho LF. Does maternal glucose intolerance affect the length of gestation in singleton pregnancies?. J Soc Gynecol Investig. 2003;10(6):366-71. Does not apply to a key question.
281 Lauenborg J, Hansen T, Jensen DM, et al. Increasing incidence of diabetes after gestational diabetes: a long-term follow-up in a Danish population. Diabetes Care. 2004;27(5):1194-9. Diagnosis of gestational diabetes not confirmed. [pmid: 15111544].
282 Lauenborg J, Mathiesen E, Hansen T, et al. The prevalence of the metabolic syndrome in a danish population of women with previous gestational diabetes mellitus is three-fold higher than in the general population. J Clin Endocrinol Metab. 2005;90(7):4004-10. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 15840755].
283 Leeman L, Leeman R. A Native American community with a 7% cesarean delivery rate: does case mix, ethnicity, or labor management explain the low rate?. Ann Fam Med. 2003;1(1):36-43. Does not apply to a key question. [pmid: 15043178].
284 Leikin E, Jenkins JH, Graves WL. Prophylactic insulin in gestational diabetes. Obstet Gynecol. 1987;70(4):587-92. Does not have a comparison of interest. [pmid: 3306510].
285 Lencioni C, Volpe L, Miccoli R, et al. Early impairment of beta-cell function and insulin sensitivity characterizes normotolerant Caucasian women with previous gestational diabetes. Nutr Metab Cardiovasc Dis. 2006;16(7):485-93. Does not evaluate risk factors for type 2 diabetes. [pmid: 17015186].
286 Leveno KJ, Fortunato SJ, Raskin P, et al. Continuous subcutaneous insulin infusion during pregnancy. Diabetes Res Clin Pract. 1988;4(4):257-268. Does not have a comparison of interest. [pmid: 3286165].
287 Levy AL, Gonzalez JL, Rappaport VJ, et al. Effect of labor induction on cesarean section rates in diabetic pregnancies. J Reprod Med Obstet Gynecol. 2002;47(11):931-932. No appropriate comparison group for KQ1.
288 Li DF, Wong VC, O'Hoy KM, et al. Is treatment needed for mild impairment of glucose tolerance in pregnancy? A randomized controlled trial. Br J Obstet Gynaecol. 1987;94(9):851-4. Does not apply to a key question. [pmid: 3311138].
289 Lin CC, River J, River P, et al. Good diabetic control early in pregnancy and favorable fetal outcome. Obstet Gynecol. 1986;67(1):51-6. Not evaluating people with gestational diabetes. [pmid: 3940338].
290 Lin CH, Wen SF, Wu YH, et al. The postpartum metabolic outcome of women with previous gestational diabetes mellitus. Chang Gung Med J. 2005;28(11):794-800. Does not evaluate risk factors for type 2 diabetes. [pmid: 16422186].
291 Liner R. Induction of labor in patients with diabetes mellitus. Am J Obstet Gynecol. 1982;143(7):850-851. Does not include original data. [pmid: 7048934].
292 Linne Y, Barkeling B, Rossner S. Natural course of gestational diabetes mellitus: long term follow up of women in the SPAWN study. BJOG. 2002;109(11):1227-31. Does not report a relative measure. [pmid: 12452459].
293 Lucarini N, Bottini FG, Borgiani P, et al. Genetic and non genetic factors in the outcome of diabetic pregnancy. J Perinat Med. 1994;22(5):379-85. Does not apply to a key question. [pmid: 7791012].
294 Mangione RA, Torre MS, DeLuca A, et al. Neonatal complications associated with maternal diabetes. Neonatal Network. 1983;2(3):36-41. Does not include original data.
295 Mannucci E, Bardini G, Ognibene A, et al. Screening for diabetes in obese patients using the new diagnostic criteria. Diabetes Care. 1998;21(3):468-9. Not evaluating people with gestational diabetes. [pmid: 9540043].
296 Manolakis PG. APhA drug treatment protocols: management of gestational diabetes mellitus and impaired glucose tolerance during pregnancy. APhA Diabetes Mellitus Panel. J Am Pharm Assoc (Wash). 1998;38(3):307-16. Does not include original data. [pmid: 9654861].
297 Maresh M, Beard RW, Bray CS, et al. Factors predisposing to and outcome of gestational diabetes. Obstet Gynecol. 1989;74(3 Pt 1):342-6. Does not have a comparison of interest. [pmid: 2761910].
298 Maresh M, Gillmer MD, Beard RW, et al. The effect of diet and insulin on metabolic profiles of women with gestational diabetes mellitus. Diabetes. 1985;34(Suppl 2):88-93. Does not have a comparison of interest. [pmid: 3888747].
299 Mashini IS, Fadel HE, Nelson GH, et al. Indications for and timing of delivery in diabetic pregnancies. Am J Obstet Gynecol. 1985;153(7):759-766. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 4073140].
300 Mathieu C. Diabetes and pregnancy: beyond glucose?. Diabetologia. 2005;48(9):1714-5. Does not include original data. [pmid: 16052328].
301 Mauricio D, Corcoy RM, Codina M, et al. Islet cell antibodies identify a subset of gestational diabetic women with higher risk of developing diabetes mellitus shortly after pregnancy. Diabetes Nutr Metab Clin Exp. 1992;5(4):237-241. Other.
302 Mawhinney H, Hadden DR, Middleton D, et al. HLA antigens in asymptomatic diabetes. A 10-year follow-up study of potential diabetes in pregnancy and gestational diabetes. Ulster Med J. 1979;48(2):166-72. Does not report a relative measure. [pmid: 505670].
303 McAuliffe FM, Foley M, Firth R, et al. Outcome of diabetic pregnancy with spontaneous labour after 38 weeks. Ir J Med Sci. 1999;168(3):160-163. Not evaluating people with gestational diabetes. [pmid: 10540779].
304 McElduff A, Hitchman R. Fasting plasma glucose values alone miss most abnormalities of glucose tolerance in the postpartum. Diabet Med. 2004;21(6):648. author reply 648–9. Does not include original data. [pmid: 15154960].
305 McFarland KF. Management of diabetes in pregnancy. J Fla Med Assoc. 1985;72(3):170-5. Does not include original data. [pmid: 3908614].
306 McGuire V, Rauh MJ, Mueller BA, et al. The risk of diabetes in a subsequent pregnancy associated with prior history of gestational diabetes or macrosomic infant. Paediatr Perinat Epidemiol. 1996;10(1):64-72. Other. [pmid: 8746432].
307 McLellan JA, Barrow BA, Levy JC, et al. Prevalence of diabetes mellitus and impaired glucose tolerance in parents of women with gestational diabetes. Diabetologia. 1995;38(6):693-8. Does not apply to a key question. [pmid: 7672491].
308 McManus RM, Cunningham I, Watson A, et al. Beta-cell function and visceral fat in lactating women with a history of gestational diabetes. Metabolism. 2001;50(6):715-9. Does not apply to a key question. [pmid: 11398150].
309 Mello G, Parretti E, Mecacci F, et al. Anthropometric features in infants of mothers with gestational diabetes: relationship with treatment modalities. Biol Neonate. 1997;72(1):22-7. Does not have a comparison of interest. [pmid: 9313831].
310 Mestman JH. Insulin resistance syndrome and gestational diabetes. Endocr Pract. 2003;9(Suppl 2):90-2. Does not include original data. [pmid: 14698984].
311 Mestman JH, Anderson GV, Guadalupe V. Follow-up study of 360 subjects with abnormal carbohydrate metabolism during pregnancy. Obstet Gynecol. 1972;39(3):421-5. Other. [pmid: 5019316].
312 Metzger BE, Coustan DR. Summary and recommendations of the Fourth International Workshop-Conference on Gestational Diabetes Mellitus. The Organizing Committee. Diabetes Care. 98;21(Suppl 2):B161-7. Does not include original data. [pmid: 9704245].
313 Metzger BE, Bybee DE, Freinkel N, et al. Gestational diabetes mellitus. Correlations between the phenotypic and genotypic characteristics of the mother and abnormal glucose tolerance during the first year postpartum. Diabetes. 1985;34(Suppl 2):111-5. Other. [pmid: 3888736].
314 Miller JM, Brown HL, Pastorek JG, et al. Fetal overgrowth. Diabetic versus nondiabetic. J Ultrasound Med. 1988;7(10):577-9. Does not apply to a key question. [pmid: 3066923].
315 Mimouni F, Miodovnik M, Rosenn B, et al. Birth trauma in insulin-dependent diabetic pregnancies. Am J Perinatol. 1992;9(3):205-8. Not evaluating people with gestational diabetes. [pmid: 1575844].
316 Mimouni F, Miodovnik M, Siddiqi TA, et al. Perinatal asphyxia in infants of insulin-dependent diabetic mothers. J PEDIATR. 1988;113(2):345-353. Not evaluating people with gestational diabetes. [pmid: 3397799].
317 Mirghani OA, Saeed OK. A simplified management of diabetic pregnant woman. Saudi Med J. 2000;21(4):335-339. Does not apply to a key question. [pmid: 11533813].
318 Moggi G, Teti G, De Luca, et al. Prevention and treatment of carbohydrate metabolism abnormalities during pregnancy. J Foetal Med. 1985;5(12):26-35. Does not include a medication of interest for KQ1.
319 Mohamed N, Dooley J. Gestational diabetes and subsequent development of NIDDM in aboriginal women of northwestern Ontario. Int J Circumpolar Health. 1998;57(Suppl 1):355-8. Does not apply to a key question. [pmid: 10093305].
320 Mokgokong ET. Management of diabetes mellitus during pregnancy by maintaining normal blood glucose levels. S Afr Med J. 83;64(26):1011-1013. Not evaluating people with gestational diabetes. [pmid: 6359489].
321 Molsted-Pedersen L, Skouby SO, Damm P. Preconception counseling and contraception after gestational diabetes. Diabetes. 1991;40(Suppl 2):147-50. Diagnosis of gestational diabetes not confirmed. [pmid: 1748246].
322 Moore Lisa, Briery Christian, Martin Rick, et al. Metformin (M) vs. insulin (I) in A2 diabetics; A randomized clinical trial: 25th Annual Meeting of the Society for Maternal-Fetal Medicine, February 7–12, 2005 Reno Hilton, Reno, Nevada. American Journal of Obstetrics and Gynecology. 2004;191(Supplement 1):S8. Does not include original data.
323 Moore MP. Diabetes and pregnancy. Improving perinatal outcome. Curr Ther. 1987;28(9):85-96. Does not include original data.
324 Moses RG. The medical management of gestational diabetes in Australia within a solo private practice. Diabet Med. 1994;11(6):597-600. Does not apply to a key question. [pmid: 7955981].
325 Moses RG, Griffiths RD. Can a diagnosis of gestational diabetes be an advantage to the outcome of pregnancy?. J Soc Gynecol Investig. 1995;2(3):523-5. Does not apply to a key question.
326 Moses RG, Knights SJ, Lucas EM, et al. Gestational diabetes: is a higher cesarean section rate inevitable?. Diabetes Care. 2000;23(1):15-7. No appropriate comparison group for KQ1. [pmid: 10857961].
327 Moses RG, Lucas EM, Knights S. Gestational diabetes mellitus. At what time should the postprandial glucose level be monitored?. Aust N Z J Obstet Gynaecol. 1999;39(4):457-60. Does not apply to a key question. [pmid: 10687763].
328 Moss JM. Treatment of pregnant diabetics with oral hypoglycemic drugs. South Med J. 1966;59(6):695-697. Case report or case series of less than 50 cases. [pmid: 5934029].
329 Murphy J, Peters J, Morris P. Conservative management of pregnancy in diabetic women. BR MED J. 1984;288(6425):1203-1205. Not evaluating people with gestational diabetes. [pmid: 6424790].
330 Naeye R L. The outcome of diabetic pregnancies: a prospective study. Ciba Found Symp 1978;(63):227–241. Not evaluating people with gestational diabetes
331 Nagy G. Management of gestational diabetes. Zentralbl Gynakol. 1993;115(4):147-53. Diagnosis of gestational diabetes not confirmed. [pmid: 8503231].
332 Nagy G. Late complications of gestational diabetes—maternal effects. Zentralbl Gynakol. 1993;115(10):450-3. Does not apply to a key question. [pmid: 8273435].
333 Nasrat HA, Salleh M, Ardawi M, et al. Outcome of pregnancy in diabetic mothers. Int J Gynaecol Obstet. 1993;43(1):29-34. Does not have a comparison of interest. [pmid: 7904950].
334 Nasrat H, Fageeh W, Abalkhail B, et al. Determinants of pregnancy outcome in patients with gestational diabetes. Int J Gynaecol Obstet. 1996;53(2):117-23. Does not apply to a key question. [pmid: 8735291].
335 Naylor CD, Sermer M, Chen E, et al. Cesarean delivery in relation to birth weight and gestational glucose tolerance: pathophysiology or practice style? Toronto Trihospital Gestational Diabetes Investigators. JAMA. 1996;275(15):1165-70. No appropriate comparison group for KQ1. [pmid: 8609683].
336 Naylor CD, Sermer M, Chen E, et al. Cesarean delivery in relation to birth weight and gestational glucose tolerance: Pathophysiology or practice style?. J Am Med Assoc. 1996;275(15):1165-1170. Other.
337 Neiger R. Fetal macrosomia in the diabetic patient. Clin Obstet Gynecol. 1992;35(1):138-150. Does not include original data. [pmid: 1544239].
338 Nestler JE. Reproductive endocrinology. Curr Opin Endocrinol Diabetes. 2002;9(6):443. Does not include original data.
339 Ng CS, Lim LS, Chng KP, et al. Combined team management of diabetes mellitus in pregnancy. Ann Acad Med Singapore. 1985;14(2):297-302. Diagnosis of gestational diabetes not confirmed. [pmid: 4037689].
340 Nord E, Hanson U, Persson B. A simplified model for management of women with gestational diabetes at the primary care level. Diabetes Res. 1991;17(4):175-9. Does not include a medication of interest for KQ1. [pmid: 1823638].
341 Nordlander E, Hanson U, Stangenberg M, et al. Twenty-four hour excretion of urinary C-peptide in gestational diabetic women before and after treatment with diet of diet and insulin. Diabetes Res. 1989;10(1):25-30. Does not apply to a key question. [pmid: 2667840].
342 Notelovitz M. Gestational diabetes in general practice. S Afr Med J. 1974;48(10):417-20. Does not include original data. [pmid: 4817054].
343 Notelovitz M. Sulphonylurea therapy in the treatment of the pregnant diabetic. S Afr Med J. 1971;45(9):226-229. Case report or case series of less than 50 cases. [pmid: 5121265].
344 Noussitou P, Monbaron D, Vial Y, et al. Gestational diabetes mellitus and the risk of metabolic syndrome: a population-based study in Lausanne, Switzerland. Diabetes Metab. 2005;31(4 Pt 1):361-9. Does not evaluate risk factors for type 2 diabetes. [pmid: 16369198].
345 O'Neill E. Gestational diabetes. Bol Asoc Med P R. 1965;57(10):508-15. Does not apply to a key question. [pmid: 5214982].
346 O'Sullivan JB, Charles D, Mahan CM, et al. Gestational diabetes and perinatal mortality rate. Am J Obstet Gynecol. 1973;116(7):901-4. Does not apply to a key question. [pmid: 4718217].
347 O'Sullivan JB, Gellis SS, Dandrow RV, et al. The potential diabetic and her treatment in pregnancy. Obstet Gynecol. 1966;27(5):683-689. No appropriate comparison group for KQ1. [pmid: 5936737].
348 Oakley NW, Beard RW, Turner RC. Effect of sustained maternal hyperglycaemia on the fetus in normal and diabetic pregnancies. Br Med J. 1972;1(798):466-469. No appropriate comparison group for KQ1. [pmid: 5008055].
349 Oats JN, Beischer NA. The persistence of abnormal glucose tolerance after delivery. Obstet Gynecol. 1990;75(3 Pt 1):397-401. Diagnosis of gestational diabetes not confirmed. [pmid: 2304711].
350 Ogata ES. Diabetes-related problems of the newborn. Perinatology Neonatology. 1984;8(1):48-53. Does not include original data.
351 Olofsson P, Ingemarsson I, Solum T. Fetal distress during labour in diabetic pregnancy. BR J Obstet Gynaecol. 1986;93(10):1067-1071. Not evaluating people with gestational diabetes. [pmid: 3790466].
352 Orskou J, Kesmodel U, Henriksen TB, et al. An increasing proportion of infants weigh more than 4000 grams at birth. Acta Obstet Gynecol Scand. 2001;80(10):931-6. Not evaluating people with gestational diabetes. [pmid: 11580738].
353 Ort T, Voss M, Lichtmacher A, et al. Pharmacogenomic assessment of treatment options in gestational diabetes. Pharmacogenomics J. 2005;5(6):338-45. Diagnosis of gestational diabetes not confirmed. [pmid: 16186854].
354 Osei K, Gaillard TR, Schuster DP. History of gestational diabetes leads to distinct metabolic alterations in nondiabetic African-American women with a parental history of type 2 diabetes. Diabetes Care. 1998;21(8):1250-7. Other. [pmid: 9702429].
355 Oztekin O. Screening for gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2006;85(6):762. author reply 763. Does not include original data. [pmid: 16752275].
356 Paisey RB, Hartog M, Savage P. A high-fibre diet in gestational diabetes—wheat fibre, leguminous fibre or both?. Hum Nutr Appl Nutr. 1987;41(2):146-9. Case report or case series of less than 50 cases. [pmid: 3032872].
357 Pallardo LF, Herranz L, Martin-Vaquero P, et al. Impaired fasting glucose and impaired glucose tolerance in women with prior gestational diabetes are associated with a different cardiovascular profile. Diabetes Care. 2003;26(8):2318-22. Does not report a relative measure. [pmid: 12882855].
358 Pedersen J, Molsted-Pedersen L M. Congenital malformations: the possible role of diabetes care outside pregnancy. Ciba Found Symp 1978;(63):265–271. Does not apply to a key question
359 Peel J. Diabetes In Pregnancy. Foetal Macrosomia And Increased Perinatal Mortality. Proc R Soc Med. 1963;56:1009-11. Does not include original data. [pmid: 14084400].
360 Perry A. Gestational diabetes. J Midwifery Womens Health. 2006;51(2):135-6. Does not include original data. [pmid: 16598891].
361 Perry RC, Dixon D. Gestational diabetes mellitus. Physician Assistant. 1999;23(5):14. Does not include original data.
362 Persson B, Stangenberg M, Hansson U, et al. Gestational diabetes mellitus (GDM): comparative evaluation of two treatment regimens, diet vs insulin and diet. Diabetes. 1985;34(Suppl 2):101-105. Not evaluating people with gestational diabetes. [pmid: 3888734].
363 Persson B, Hanson U, Hartling SG, et al. Follow-up of women with previous GDM. Insulin, C-peptide, and proinsulin responses to oral glucose load. Diabetes. 1991;40(Suppl 2):136-41. Does not evaluate risk factors for type 2 diabetes. [pmid: 1748243].
364 Persson B, Stangenberg M, Hansson U, et al. Gestational diabetes mellitus (GDM). Comparative evaluation of two treatment regimens, diet versus insulin and diet. Diabetes. 85;34(Suppl 2):101-5. Not evaluating people with gestational diabetes. [pmid: 3888734].
365 Pettitt DJ, Ospina P, Kolaczynski JW, et al. Comparison of an insulin analog, insulin aspart, and regular human insulin with no insulin in gestational diabetes mellitus. Diabetes Care. 2003;26(1):183-6. Other. [pmid: 12502678].
366 Philipson EH, Kalhan SC, Edelberg SC, et al. Maternal obesity as a risk factor in gestational diabetes. Am J Perinatol. 1985;2(4):268-70. Does not apply to a key question. [pmid: 4052176].
367 Philipson EH, Kalhan SC, Rosen MG, et al. Gestational diabetes mellitus. Is further improvement necessary?. Diabetes. 1985;34(Suppl 2):55-60. Does not have a comparison of interest. [pmid: 3888743].
368 Piacquadio K, Hollingsworth DR, Murphy H. Effects of in-utero exposure to oral hypoglycaemic drugs. Lancet. 1991;338(8771):866-9. Not evaluating people with gestational diabetes. [pmid: 1681225].
369 Pimenta WP, Calderon IM, Cruz NS, et al. Subclinical abnormalities of glucose metabolism in Brazilian women with a history of gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2004;83(12):1152-8. Does not evaluate risk factors for type 2 diabetes. [pmid: 15548148].
370 Piscitelli J, Eden RD, Jelovsek FR, et al. Family history of diabetes mellitus and oral glucose tolerance testing criteria. Acta Obstet Gynecol Scand. 1987;66(6):489-492. Does not apply to a key question. [pmid: 3425251].
371 Plehwe WE, Shearman RP, Turtle JR. Management of pregnancy complicated by diabetes: experience with 232 patients in a 4-year period. Aust N Z J Obstet Gynaecol. 1984;24(3):167-73. Not evaluating people with gestational diabetes. [pmid: 6393944].
372 Pullen F, Thompson T, Drubra U. A nurse-led clinic for women with IGT following gestational diabetes. Impaired glucose tolerance [corrected] [published erratum appears in J Diabetes Nurs 1998 Sep–Oct; 2(5): 138]. Journal of Diabetes Nursing. 98;2(4):115-118. Does not apply to a key question.
373 Pullen F, Grenfell A. The diagnosis of gestational diabetes in a multiethnic population: Which diagnostic criteria should be used with respect to maternal outcome?. Pract Diabetes Int. 2002;19(9):279-282. Other.
374 Rajab KE, Mehdi S. Pregnancy outcome among gestational diabetics with blood glucose levels between 7.7 and 8.3 mmol/l. Int J Gynaecol Obstet. 1998;63(1):59-61. Does not apply to a key question. [pmid: 9849714].
375 Ramos-Arroyo MA, Rodriguez-Pinilla E, Cordero JF. Maternal diabetes: the risk for specific birth defects. Eur J Epidemiol. 1992;8(4):503-8. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 1397216].
376 Ranade AY, Merchant RH, Bajaj RT, et al. Infants of diabetic mothers—an analysis of 50 cases. Indian Pediatr. 1989;26(4):366-370. No appropriate comparison group for KQ1. [pmid: 2599599].
377 Rand L, Caughey AB. Comparison of glyburide and insulin for the management of gestational diabetes in a large managed care organization. Am J Obstet Gynecol. 2006;195(2):628-9. author reply 629–30. Does not include original data. [pmid: 16579949].
378 Rasmussen MJ, Firth R, Foley M, et al. The timing of delivery in diabetic pregnancy: A 10-Year review. Aust New Zealand J Obstet Gynaecol. 1992;32(4):313-317. Not evaluating people with gestational diabetes. [pmid: 1290426].
379 Ravina A. Insulin-dependent diabetes of pregnancy treated with the combination of sulfonylurea and insulin. Isr J Med Sci. 1995;31(10):623-5. Case report or case series of less than 50 cases. [pmid: 7591687].
380 Ray JG, Vermeulen MJ, Shapiro JL, et al. Maternal and neonatal outcomes in pregestational and gestational diabetes mellitus, and the influence of maternal obesity and weight gain: the DEPOSIT study. Diabetes Endocrine Pregnancy Outcome Study in Toronto. QJM. 2001;94(7):347-56. Does not apply to a key question. [pmid: 11435630].
381 Raychaudhuri K, Maresh MJ. Glycemic control throughout pregnancy and fetal growth in insulin-dependent diabetes. Obstet Gynecol. 2000;95(2):190-4. Not evaluating people with gestational diabetes. [pmid: 10674578].
382 Reader D, Splett P, Gunderson EP, et al. Impact of gestational diabetes mellitus nutrition practice guidelines implemented by registered dietitians on pregnancy outcomes. Journal of the American Dietetic Association. 2006;106(9):1426-33. No appropriate comparison group for KQ1. [pmid: 16963348].
383 Remsberg KE, McKeown RE, McFarland KF, et al. Diabetes in pregnancy and cesarean delivery. Diabetes Care. 1999;22(9):1561-7. Does not apply to a key question. [pmid: 10480526].
384 Retnakaran R, Hanley AJ, Raif N, et al. Reduced adiponectin concentration in women with gestational diabetes: a potential factor in progression to type 2 diabetes. Diabetes Care. 2004;27(3):799-800. Does not apply to a key question. [pmid: 14988306].
385 Ricart W, Bach C, Fernandez-Real JM, et al. Major fetal complications in optimised progestational diabetes mellitus. Diabetologia. 2000;43(8):1077-8. Not evaluating people with gestational diabetes. [pmid: 10990089].
386 Roach V, Rogers M. The incidence of perinatal mortality associated with hyperglycaemia in pregnancy. Aust N Z J Obstet Gynaecol. 1997;37(2):250-1. Does not include original data. [pmid: 9222483].
387 Roberts AB, Baker JR, James AG, et al. Fructosamine in the management of gestational diabetes. Am J Obstet Gynecol. 1988;159(1):66-71. Does not apply to a key question. [pmid: 3394755].
388 Romon M, Nuttens MC, Vambergue A, et al. Higher carbohydrate intake is associated with decreased incidence of newborn macrosomia in women with gestational diabetes. J Am Diet Assoc. 2001;101(8):897-902. Does not apply to a key question. [pmid: 11501863].
389 Roncaglia N, Bellini P, Arreghini A, et al. Gestational diabetes mellitus: intensive versus mild treatment. Clin Exp Obstet Gynecol. 1999;26(2):95-7. Does not apply to a key question. [pmid: 10459448].
390 Roseman JM, Go RC, Perkins LL, et al. Gestational diabetes mellitus among African-American women. Diabetes Metab Rev. 1991;7(2):93-104. Does not apply to a key question. [pmid: 1794260].
391 Ross G. Gestational diabetes. Aust Fam Physician. 2006;35(6):392-6. Does not include original data. [pmid: 16751853].
392 Ruder K. Family ties. Diabetes during pregnancy carries a lifelong risk of type 2 for mother and child. Diabetes Forecast 2006;59(12):54–6, 58. Does not include original data
393 Russell MA, Phipps MG, Olson CL, et al. Rates of postpartum glucose testing after gestational diabetes mellitus. Obstet Gynecol. 2006;108(6):1456-62. Does not apply to a key question. [pmid: 17138780].
394 Rutten GEHM, Boomsma LJ. Detection of type 2 diabetes mellitus in general practice: Do the patients' dossiers provide clues?. Pract Diabetes Int. 2000;17(5):152-154. Not evaluating people with gestational diabetes.
395 Ryan EA, Imes S, Liu D, et al. Defects in insulin secretion and action in women with a history of gestational diabetes. Diabetes. 1995;44(5):506-12. Other. [pmid: 7729607].
396 Saade G. Gestational diabetes mellitus: a pill or a shot?. Obstet Gynecol. 2005;105(3):456-7. Does not include original data. [pmid: 15738007].
397 Salzberger M, Sharon A, Liban E. Significance of the oral glucose tolerance test performed on the third day after delivery for the diagnosis of diabetes in pregnancy. Isr J Med Sci. 1975;11(6):629-31. Does not apply to a key question. [pmid: 1158671].
398 Sameshima H, Ikenoue T, Kawahara S, et al. Effects of longitudinal maternal glucose control of infants of diabetic mothers. Acta Obstet Gynaecol Jpn. 1991;43(7):779-782. Does not include a medication of interest for KQ1.
399 Sameshima H, Kamitomo M, Kajiya S, et al. Early glycemic control reduces large-for-gestational-age infants in 250 Japanese gestational diabetes pregnancies. Am J Perinatol. 2000;17(7):371-6. Does not apply to a key question. [pmid: 12141524].
400 Schaefer-Graf UM, Buchanan TA, Xiang AH, et al. Clinical predictors for a high risk for the development of diabetes mellitus in the early puerperium in women with recent gestational diabetes mellitus. Am J Obstet Gynecol. 2002;186(4):751-756. Other. [pmid: 11967502].
401 Schaefer-Graf UM, Buchanan TA, Xiang A, et al. Patterns of congenital anomalies and relationship to initial maternal fasting glucose levels in pregnancies complicated by type 2 and gestational diabetes. Am J Obstet Gynecol. 2000;182(2):313-20. Not evaluating people with gestational diabetes. [pmid: 10694330].
402 Schaefer-Graf UM, Kjos SL, Fauzan OH, et al. A randomized trial evaluating a predominately fetal growth-based strategy to guide management of gestational diabetes in Caucasian women. Diabetes Care. 2004;27(2):297-302. Other. [pmid: 14747203].
403 Scherbaum WA, Lankisch MR, Pawlowski B, et al. Insulin Lispro in pregnancy - Retrospective analysis of 33 cases and matched controls. Exp Clin Endocrinol Diabetes. 2002;110(1):6-9. Not evaluating people with gestational diabetes. [pmid: 11835118].
404 Schranz AG, Savona-Ventura C. Long-term significance of gestational carbohydrate intolerance: a longitudinal study. Exp Clin Endocrinol Diabetes. 2002;110(5):219-22. Not evaluating people with gestational diabetes. [pmid: 12148085].
405 Schwartz R, Teramo KA. Pregnancy outcome, Diabetes Control and Complications Trial, and intensive glycemic control. Am J Obstet Gynecol. 1998;178(2):416-7. Does not include original data. [pmid: 9500510].
406 Schwarz RH, Fields GA, Kyle GC. Timing of delivery in the pregnant diabetic patient. Obstet Gynecol. 1969;34(6):787-791. No appropriate comparison group for KQ1. [pmid: 5366021].
407 Scupholme A, Kamons AS. Validating change in risk criteria for a birth center: gestational diabetes. J Nurse Midwifery. 1988;33(3):129-33. Does not apply to a key question. [pmid: 3404275].
408 Seely EW. Does treatment of gestational diabetes mellitus affect pregnancy outcome?. Nat Clin Pract Endocrinol Metab. 2006;2(2):72-3. Does not include original data. [pmid: 16932258].
409 Semchyshyn S. A new approach to the treatment of diabetic pregnant women. Am J Obstet Gynecol. 1981;139(8):975-979. Case report or case series of less than 50 cases. [pmid: 7013483].
410 Sendag F, Terek MC, Itil IM, et al. Maternal and perinatal outcomes in women with gestational diabetes mellitus as compared to nondiabetic controls. J Reprod Med. 2001;46(12):1057-62. Does not have a comparison of interest. [pmid: 11789086].
411 Senior B. Neonatal hypoglycemia. N Engl J Med. 1973;289(15):790-793. Does not include original data. [pmid: 4728751].
412 Serirat S, Deerochanawong C, Sunthornthepvarakul T, et al. Gestational diabetes mellitus. J Med Assoc Thai. 92;75(6):315-9. Does not apply to a key question. [pmid: 1487678].
413 Serr DM, Ismajovitch B, Mashiach S, et al. Effect of insulin on perinatal mortality in gestational diabetes. Isr J Med Sci. 1972;8(6):789. Does not apply to a key question. [pmid: 5051795].
414 Shanmugasundaram L. Outcome of type I and type II diabetic pregnancy in Asian women. BJOG. 2006;113(4):495-6. author reply 496. Does not include original data. [pmid: 16553667].
415 Shea MA, Garrison DL, Tom SK. Diabetes in pregnancy. Am J Obstet Gynecol. 1971;111(6):801-3. Does not apply to a key question. [pmid: 5166390].
416 Shearman RP. Diabetes in pregnancy. Med J Aust. 1987;146(4):181-2. Does not include original data. [pmid: 3574207].
417 Shushan A, Ezra Y, Samueloff A. Early treatment of gestational diabetes reduces the rate of fetal macrosomia. Am J Perinatol. 1997;14(5):253-6. Does not apply to a key question. [pmid: 9259938].
418 Silver HJ. Nutritional management of diabetes in pregnancy. J Am Diet Assoc. 1993;93(12):1381-2. Does not include original data. [pmid: 8245370].
419 Simhayoff N, Sheiner E, Levy A, et al. To induce or not to induce labor: a macrosomic dilemma. Gynecol Obstet Invest. 2004;58(3):121-5. Not evaluating people with gestational diabetes. [pmid: 15467303].
420 Simmons D. Gestational diabetes mellitus: growing consensus on management but not diagnosis. N Z Med J. 1999;112(1082):45-6. Does not include original data. [pmid: 10091890].
421 Simmons D, Robertson S. Influence of maternal insulin treatment on the infants of women with gestational diabetes. Diabet Med. 1997;14(9):762-5. Does not have a comparison of interest. [pmid: 9300226].
422 Simmons D, Flack JR, McIntyre HD. Auditing diabetes in pregnancy care in New Zealand. N Z Med J. 2006;119(1230):U1897. Does not include original data. [pmid: 16532058].
423 Simmons D, Thompson CF, Conroy C, et al. Use of insulin pumps in pregnancies complicated by type 2 diabetes and gestational diabetes in a multiethnic community. Diabetes Care. 2001;24(12):2078-82. Not evaluating people with gestational diabetes. [pmid: 11723086].
424 Simpson RW, Kast SJ. Management of gestational diabetes with a conservative insulin protocol. Med J Aust. 2000;172(11):537-40. Does not apply to a key question. [pmid: 10920751].
425 Sinha B, Dunne F. A postpartum screening strategy following gestational diabetes. Diabetes Primary Care. 2001;3(2):44-46. Other.
426 Sinha B, Brydon P, Taylor RS, et al. Maternal ante-natal parameters as predictors of persistent postnatal glucose intolerance: a comparative study between Afro-Caribbeans, Asians and Caucasians. Diabet Med. 2003;20(5):382-6. Does not apply to a key question. [pmid: 12752487].
427 Skouby SO, Andersen O, Kuhl C. Oral contraceptives and insulin receptor binding in normal women and those with previous gestational diabetes. Am J Obstet Gynecol. 1986;155(4):802-7. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 3766633].
428 Skouby SO, Kuhl C, Hornnes PJ, et al. Prolactin and glucose tolerance in normal and gestational diabetic pregnancy. Obstet Gynecol. 1986;67(1):17-20. Not evaluating people with gestational diabetes. [pmid: 3510013].
429 Skyler JS, O'Sullivan MJ, Robertson EG. Blood glucose control during pregnancy. Diabetes Care. 1980;3(1):69-76. Not evaluating people with gestational diabetes. [pmid: 6996971].
430 Slawson D. Do certain forms of contraception given to women with gestational diabetes mellitus increase their risk of developing type 2 diabetes? Evidence-Based Practice 1998;1(11):9–10, insert 2p. Other
431 Smith SG, Scragg WH. Gestational diabetes. Obstet Gynecol. 1968;31(2):228-39. Does not apply to a key question. [pmid: 4867056].
432 Spellacy WN. Shoulder dystocia risks. Am J Obstet Gynecol. 1999;180(4):1047. Does not include original data. [pmid: 10203684].
433 Sperling MA, Menon RK. Infant of the diabetic mother. Curr Ther Endocrinol Metab. 1994;5:372-6. Does not include original data. [pmid: 7704757].
434 Stage E, Ronneby H, Damm P. Lifestyle change after gestational diabetes. Diabetes Res Clin Pract. 2004;63(1):67-72. No relevant risk factor for KQ3. [pmid: 14693414].
435 Stallone LA, Ziel HK. Management of gestational diabetes. Am J Obstet Gynecol. 1974;119(8):1091-4. Does not apply to a key question. [pmid: 4847444].
436 Stangenberg M, Agarwal N, Rahman F, et al. Frequency of HLA genes and islet cell antibodies (ICA) and result of postpartum oral glucose tolerance tests (OGTT) in Saudi Arabian women with abnormal OGTT during pregnancy. Diabetes Res. 1990;14(1):9-13. Does not evaluate risk factors for type 2 diabetes. [pmid: 2134668].
437 Stangenberg M, Persson B, Lunell NO, et al. Effect of treatment with insulin or diet on intermediary metabolites in pregnant women with chemical diabetes in the third trimester of pregnancy. Acta Diabetol Lat. 1984;21(1):55-61. Does not have a comparison of interest. [pmid: 6375226].
438 Steel JM, Campbell IW, Hellmuth E, et al. Oral hypoglycaemic agents in 188 diabetic pregnancies. Diabetic Med. 2001;18(7):604-605. Does not include original data. [pmid: 11553194].
439 Stephenson MJ. Gestational diabetes mellitus. Can Fam Physician. 1993;39:745-53. Does not include original data. [pmid: 8495130].
440 Stoffel M, Bell KL, Blackburn CL, et al. Identification of glucokinase mutations in subjects with gestational diabetes mellitus. Diabetes. 1993;42(6):937-40. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 8495817].
441 Stowers JM, Sutherland HW, Kerridge DF. Long-range implications for the mother. The Aberdeen experience. Diabetes. 1985;34(Suppl 2):106-10. Diagnosis of gestational diabetes not confirmed. [pmid: 3888735].
442 Strehlow SL, Mestman JH. Prevention of T2DM in women with a previous history of GDM. Curr Diabetes Rep. 2005;5(4):272-277. Does not include original data.
443 Sugiyama Y, Kozuka Y, Tamura H. The studies of pregnant women with diabetes mellitus or gestational diabetes. Acta Obstet Gynaecol Jpn. 1974;21(3):127-34. Does not apply to a key question. [pmid: 4470674].
444 Sun Y, Wang JH, Qi XY. The 1:3 matched case-control study of genetic mutations of gestational diabetes mellitus. Chin Med Sci J. 2005;20(2):141. No relevant risk factor for KQ3. [pmid: 16075759].
445 Sunehag A, Berne C, Lindmark G, et al. Gestational diabetes-perinatal outcome with a policy of liberal and intensive insulin therapy. Ups J Med Sci. 1991;96(3):185-98. Does not have a comparison of interest. [pmid: 1810078].
446 Svare JA, Hansen BB, Molsted-Pedersen L. Perinatal complications in women with gestational diabetes mellitus. Acta Obstet Gynecol Scand. 2001;80(10):899-904. No appropriate comparison group for KQ1. [pmid: 11580734].
447 Svare JA, Hansen BB, Molsted-Pedersen L. Perinatal complications in women with gestational diabetes mellitus: Significance of a diagnosis early in pregnancy. Acta Obstet Gynecol Scand. 2001;80(10):899-904. Other. [pmid: 11580734].
448 Szilagyi A, Szabo I. Improvement of perinatal outcome in diabetic pregnant women. Early Pregnancy. 2001;5(1):55-6. Does not include original data. [pmid: 11753514].
449 Tan YY, Yeo SH, Liauw PC. Is postnatal oral glucose tolerance testing necessary in all women with gestational diabetes. Singapore Med J. 1996;37(4):384-8. Does not apply to a key question. [pmid: 8993138].
450 Tanir HM, Sener T, Gurer H, et al. A ten-year gestational diabetes mellitus cohort at a university clinic of the mid-Anatolian region of Turkey. Clin Exp Obstet Gynecol. 2005;32(4):241-4. Does not apply to a key question. [pmid: 16440823].
451 Taricco E, Radaelli T, Nobile de, et al. Foetal and placental weights in relation to maternal characteristics in gestational diabetes. Placenta. 2003;24(4):343-7. Does not apply to a key question. [pmid: 12657507].
452 Tee CS, Wang KW, Tho CK, et al. Management and outcome of gestational diabetes in Alexandra Hospital, Singapore. Ann Acad Med Singapore. 1990;19(4):459-62. No appropriate comparison group for KQ1. [pmid: 2221803].
453 Thatcher R. A review of 806 caesarean operations performed at the Queen Victoria Maternity Hospital, Adelaide, in the years 1965-1969. Med J Aust. 1970;2(5):231-232. Not evaluating people with gestational diabetes. [pmid: 4989513].
454 Thompson DM, Dansereau J, Creed M, et al. Tight glucose control results in normal perinatal outcome in 150 patients with gestational diabetes. Obstet Gynecol. 1994;83(3):362-6. Does not have a comparison of interest. [pmid: 8127526].
455 Todros T, Meriggi E, Catella G, et al. Growth of fetuses of diabetic mothers. J Clin Ultrasound. 1989;17(5):333-337. Does not apply to a key question. [pmid: 2499597].
456 Toescu V, Nuttall SL, Kendall MJ, et al. Women with gestational diabetes should be targeted to reduce cardiovascular risk. BMJ. 2002;325(7370):966. Does not include original data. [pmid: 12399355].
457 Tuffnell D, West J, Walkinshaw S. Time to screen for, and treat, gestational diabetes. BJOG. 2006;113(1):3-4. Does not include original data. [pmid: 16398763].
458 Tura A, Mari A, Winzer C, et al. Impaired beta-cell function in lean normotolerant former gestational diabetic women. Eur J Clin Invest. 2006;36(1):22-8. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 16403006].
459 Usher RH, Allen AC, McLean FH. Risk of respiratory distress syndrome related to gestational age, route of delivery, and maternal diabetes. Am J Obstet Gynecol. 1971;111(6):826-832. Other. [pmid: 5209554].
460 Van Assche FA. Fetal consequences of maternal diabetes. Verh K Acad Geneeskd Belg. 1987;49(6):445-60. Does not apply to a key question. [pmid: 3448832].
461 van der Linden SJ, Mastboom JL. Insulin treatment of latent and potential diabetics during pregnancy. J Obstet Gynaecol Br Commonw. 1971;78(10):924-926. No appropriate comparison group for KQ1. [pmid: 4939283].
462 Van Howe RS, Storms MR. Hypoglycemia in infants of diabetic mothers: experience in a rural hospital. Am J Perinatol. 2006;23(2):105-10. Not evaluating people with gestational diabetes. [pmid: 16506116].
463 Van Wootten W, Turner RE. Macrosomia in neonates of mothers with gestational diabetes is associated with body mass index and previous gestational diabetes. J Am Diet Assoc. 2002;102(2):241-3. Does not apply to a key question. [pmid: 11846118].
464 Vaughan NJ. Treatment of diabetes in pregnancy. Br Med J (Clin Res Ed). 1987;294(6571):558-60. Does not include original data.
465 Verma A, Boney CM, Tucker R, et al. Insulin resistance syndrome in women with prior history of gestational diabetes mellitus. J Clin Endocrinol Metab. 2002;87(7):3227-35. Other. [pmid: 12107230].
466 Vitoratos N, Salamalekis E, Loghis S, et al. Changes of glucose tolerance after delivery in women with gestational diabetes. Clin Exp Obstet Gynecol. 2000;27(34):212-4. Does not apply to a key question. [pmid: 11214954].
467 Vohr BR, McGarvey ST, Coll CG. Effects of maternal gestational diabetes and adiposity on neonatal adiposity and blood pressure. Diabetes Care. 1995;18(4):467-75. Does not have a comparison of interest. [pmid: 7497855].
468 Walsh E. Re: Gestational diabetes. What happens post-partum?. Aust N Z J Obstet Gynaecol. 2004;44(3):277-8. Does not include original data. [pmid: 15191465].
469 Walters BN. Re: Australian carbohydrate intolerance study in pregnant women: implications for the management of gestational diabetes. Aust N Z J Obstet Gynaecol. 2006;46(5):463-4. author reply 464. Does not include original data. [pmid: 16953867].
470 Ward WK, Johnston CL, Beard JC, et al. Abnormalities of islet B-cell function, insulin action, and fat distribution in women with histories of gestational diabetes: relationship to obesity. J Clin Endocrinol Metab. 1985;61(6):1039-45. Other. [pmid: 3902865].
471 Watson D, Rowan J, Neale L, et al. Admissions to neonatal intensive care unit following pregnancies complicated by gestational or type 2 diabetes. Aust N Z J Obstet Gynaecol. 2003;43(6):429-32. Does not apply to a key question. [pmid: 14712945].
472 Weaver SP. New research gestational diabetes indicates risk later in life. Fam Med. 2004;36(3):159-60. Does not include original data. [pmid: 14999567].
473 Wechter DJ, Kaufmann RC, Amankwah KS, et al. Prevention of neonatal macrosomia in gestational diabetes by the use of intensive dietary therapy and home glucose monitoring. Am J Perinatol. 1991;8(2):131-4. Does not apply to a key question. [pmid: 2006939].
474 Weeks JW, Major CA, de Veciana M, et al. Gestational diabetes: does the presence of risk factors influence perinatal outcome?. Am J Obstet Gynecol. 1994;171(4):1003-7. Does not apply to a key question. [pmid: 7943062].
475 Weeks JW, Pitman T, Spinnato JA, et al. Fetal macrosomia: does antenatal prediction affect delivery route and birth outcome?. Am J Obstet Gynecol. 1995;173(4):1215-9. Not evaluating people with gestational diabetes. [pmid: 7485323].
476 Wein P, Beischer NA, Sheedy MT. Studies of postnatal diabetes mellitus in women who had gestational diabetes. Part 2. Prevalence and predictors of diabetes mellitus after delivery. Aust N Z J Obstet Gynaecol. 1997;37(4):420-3. Diagnosis of gestational diabetes not confirmed. [pmid: 9429704].
477 Wein P, Beischer N, Harris C, et al. A trial of simple versus intensified dietary modification for prevention of progression to diabetes mellitus in women with impaired glucose tolerance. Aust N Z J Obstet Gynaecol. 1999;39(2):162-6. Diagnosis of gestational diabetes not confirmed. [pmid: 10755770].
478 Weiss PA. Prophylactic insulin in gestational diabetes. Obstet Gynecol. 1988;71(6 Pt 1):951-2. Does not include original data. [pmid: 3285276].
479 Weiss PA, Hofmann HM, Kainer F, et al. Fetal outcome in gestational diabetes with elevated amniotic fluid insulin levels. Dietary versus insulin treatment. Diabetes Res Clin Pract. 1988;5(1):1-7. Diagnosis of gestational diabetes not confirmed. [pmid: 3042342].
480 Weng J, Ekelund M, Lehto M, et al. Screening for MODY mutations, GAD antibodies, and type 1 diabetes—associated HLA genotypes in women with gestational diabetes mellitus. Diabetes Care. 2002;25(1):68-71. Does not apply to a key question. [pmid: 11772903].
481 Wheeler FC, Gollmar CW, Deeb LC. Diabetes and pregnancy in South Carolina: prevalence, perinatal mortality, and neonatal morbidity in 1978. Diabetes Care. 1982;5(6):561-5. Not evaluating people with gestational diabetes. [pmid: 6985451].
482 Wijeyaratne CN, Waduge R, Arandara D, et al. Metabolic and polycystic ovary syndromes in indigenous South Asian women with previous gestational diabetes mellitus. BJOG. 2006;113(10):1182-7. Does not evaluate a relevant maternal or neonatal outcome. [pmid: 16972862].
483 Williger VM. Fetal outcome in the diabetic pregnancy. Am J Obstet Gynecol. 1966;94(1):57-61. Not evaluating people with gestational diabetes. [pmid: 5947988].
484 Winzer C, Wagner O, Festa A, et al. Plasma adiponectin, insulin sensitivity, and subclinical inflammation in women with prior gestational diabetes mellitus. Diabetes Care. 2004;27(7):1721-7. Does not apply to a key question. [pmid: 15220253].
485 Xiang AH, Wang C, Peters RK, et al. Coordinate changes in plasma glucose and pancreatic beta-cell function in Latino women at high risk for type 2 diabetes. Diabetes. 2006;55(4):1074-9. Does not report a relative measure. [pmid: 16567531].
486 Yan JS, Chang YK, Yin CS. Elective cesarean section for macrosomia?. Zhonghua Yi Xue Za Zhi (Taipei). 1994;53(3):141-5. Does not apply to a key question. [pmid: 8174008].
487 Yang X, Hsu-Hage BH, Dong L, et al. Postpartum glucose intolerance in Chinese women with gestational diabetes. Diabet Med. 2003;20(8):687-9. Does not include original data. [pmid: 12873301].
488 Yogev Y, Ben-Haroush A, Chen R, et al. Active induction management of labor for diabetic pregnancies at term; mode of delivery and fetal outcome—a single center experience. Eur J Obstet Gynecol Reprod Biol. 2004;114(2):166-70. Not evaluating people with gestational diabetes. [pmid: 15140510].
489 Yorav S, Homburg R, Zakut H. Fetal macrosomia. Clinical factors and implications. J Foetal Med. 1987;7(12):40-43. Not evaluating people with gestational diabetes.
490 Yue DK, Molyneaux LM, Ross GP, et al. Why does ethnicity affect prevalence of gestational diabetes? The underwater volcano theory. Diabet Med. 1996;13(8):748-52. Does not apply to a key question. [pmid: 8862951].
491 Yun S, Kabeer NH, Zhu BP, et al. Modifiable risk factors for developing diabetes among women with previous gestational diabetes. Prev Chronic Dis. 2007;4(1):A07. Not evaluating people with gestational diabetes. [pmid: 17173715].
492 Zarowitz H, Moltz A. Management of diabetes in pregnancy. Obstet Gynecol. 1966;27(6):820-6. Does not apply to a key question. [pmid: 5935435].
493 Zelop CM, Shipp TD, Repke JT, et al. Outcomes of trial of labor following previous cesarean delivery among women with fetuses weighing >4000 g. Am J Obstet Gynecol. 2001;185(4):903-5. Not evaluating people with gestational diabetes. [pmid: 11641675].
494 Zhu L, Nakabayashi M, Takeda Y. Statistical analysis of perinatal outcomes in pregnancy complicated with diabetes mellitus. J Obstet Gynaecol Res. 1997;23(6):555-63. Not evaluating people with gestational diabetes. [pmid: 9433048].
495 Zonenberg A, Telejko B, Topolska J, et al. Factors predisposing to disturbed carbohydrate tolerance in patients with previous gestational diabetes mellitus. Diabetol Dosw Klin. 2006;6(3):143-150. Does not have a comparison of interest.
496 Zoupas Ch, Mastrantonakis E, Diakakis I. The importance of insulin administration in gestational diabetics. Acta Endocrinol Suppl. 1984;107(265):26-28. Does not have a comparison of interest.