# Appendix C: Detailed Electronic Database Search Strategies

MEDLINE Strategy

Terms | Returns
(Diabetes, gestational[mh] OR gestational diabet*[tiab] OR diabetes in pregnancy[tiab] OR (diabet*[tiab] AND gestation*[tiab])) AND (((Insulin[mh] OR Insulin[tiab]) OR (sulfonylurea compounds[mh] OR hypoglycemics[tiab] OR hypoglycemic agents[tiab] OR Glyburide[tiab] OR Glipizide[tiab] OR glimepiride[tiab]) OR (Biguanides[mh] OR biguanide*[tiab] OR Metformin[tiab]) OR (Pregnancy[mh] OR Pregnan*[tiab] OR Pregnancy complications[mh] OR treatment outcome[mh] OR treatment outcome*[tiab]) OR (labor, induced[mh] OR Induced labor[tiab] OR Induction of labor[tiab] OR Obstetric Labor[mh] OR Cesarean section[mh] OR cesarean*[tiab] OR C-section[tiab] OR Abdominal deliver*[tiab]) OR (Diabetes Mellitus, Type 2[mh] OR (Diabet*[tiab] AND type 2[tiab]) OR (Diabet*[tiab] AND type II[tiab])))) AND eng[la] NOT (animals[mh]NOT humans[mh]) | 5628

EMBASE Strategy

(((((((‘pregnancy diabetes mellitus’/exp) OR (‘gestational diabetes’)) OR ((‘pregnancy’/exp) AND (‘non insulin dependent diabetes mellitus’/exp))) OR ((‘type 2 diabetes’ OR ‘type ii diabetes’ OR ‘diabetes mellitus’) AND (pregnant OR pregnancy))) AND ((((‘antidiabetic agent’/exp) OR (hypoglycemic) OR (‘hypoglycemic agent’)) OR (insulin)) OR ((‘risk factor’) OR (‘treatment outcome’/exp) OR (‘treatment outcome’) OR (‘pregnancy outcome’/exp) OR (‘pregnancy outcome’) OR (benefit) OR (‘adverse event’) OR (comorbidity)) OR ((‘labor’/exp) OR (‘labor induction’/exp) OR (‘induced labor’) OR (‘cesarean section’)) OR (‘reproducibility’/exp)))) AND [english]/lim AND [humans]/lim) NOT [review]/lim | 5306

The Cochrane Central Register of Controlled Trials (CENTRAL)

#1 MeSH descriptor Diabetes, Gestational explode all trees | 225
#2 (gestational diabetes) or (gestational diabetes):ti or (gestational diabetes):ab or (gestational diabetes):kw
#3 (#1 OR #2)
#4 MeSH descriptor Diabetes Mellitus, Type 2 explode all trees
#5 (diabetes) or (diabetes):ti or (diabetes):ab or (diabetes):kw
#6 (#4 OR #5)
#7 MeSH descriptor Labor, Induced explode all trees
#8 (labor) or (labor):ti or (labor):ab or (labor):kw
#9 (Induc*) or (Induc*):ti or (Induc*):ab or (Induc*):kw
#10 (#8 AND #9)
#11 (#7 OR #10)
#12 MeSH descriptor Cesarean Section explode all trees
#13 (cesarean*) or (cesarean*):ti or (cesarean*):ab or (cesarean*):kw
#14 (caesarean*) or (caesarean*):ti or (caesarean*):kw or (caesarean*):ab
#15 (#14 AND NOT #13)
#16 (#13 OR #14)
#17 MeSH descriptor Insulin explode all trees
#18 (insulin) or (insulin):ti or (insulin):kw or (insulin):ab
#19 MeSH descriptor Sulfonylurea Compounds explode all trees
#20 (glyburide) or (glyburide):ti or (glyburide):kw or (glyburide):ab
#21 (glipizide) or (glipizide):ti or (glipizide):kw or (glipizide):ab
#22 (glimepiride) or (glimepiride):ti or (glimepiride):kw or (glimepiride):ab
#23 (#17 OR #18)
#24 (#19 OR #20 OR #21 OR #22)
#25 MeSH descriptor Metformin explode all trees
#26 (Metformin) or (Metformin):ti or (Metformin):kw or (Metformin):ab
#27 (#25 OR #26)
#28 (#12 OR #16)
#29 MeSH descriptor Pregnancy Complications explode all trees
#30 MeSH descriptor Pregnancy explode all trees
#31 (pregnan*) or (pregnan*):ti or (pregnan*):kw or (pregnan*):ab
#32 MeSH descriptor Risk explode all trees
#33 (risk*) or (risk*):ti or (risk*):kw or (risk*):ab
#34 (#29 OR #30 OR #31)
#35 (#32 OR #33)
#36 (#23 OR #24 OR #27)
#37 (#3 AND ( #11 OR #28 OR #36 OR #34 OR #35 ))

Cumulative Index to Nursing and Applied Health Literature (CINAHL)

((MH Diabetes Mellitus, Gestational) OR (MH Diabetes Mellitus, Non-Insulin-Dependent) OR (TX “gestational diabetes”) OR ((TX “type 2 diabetes” OR TX “type II diabetes” OR (TX diabetes and TX ( “type II” OR “type 2” ))) AND TX Pregnancy) OR (TX Pregnancy and TX diabetes) OR (TX “diabetes in pregnancy”)) AND (( MH “pregnancy outcomes” or MH “Pregnancy Complications” or MH comorbidity ) OR (TX ( Maternal OR neonatal OR pregnancy ) and TX ( “adverse event” OR benefit OR risk OR complication OR complications OR outcome OR outcomes ) )) OR ((MH insulin or MH hypoglycemic agents or MH sulfonylurea compounds ) OR (TX ( hypoglycemics OR “hypoglycemic agents” OR sulfonylurea OR metformin ) )) OR (TX ( “diagnostic test” OR “diagnostic tests” ) or MH ( “sensitivity and specificity” ) or MH “reproducibility of results” )) NOT ( review OR “meta-analysis” OR “meta analysis” OR metaanalysis ) and LA English | 2907