# Appendix B: Hand Searched Journals

All Journals Hand Searched

August 2006 – January 2007

Acta Obstetricia et Gynecologica Scandinavica

American Journal of Obstetrics and Gynecology

American Journal of Perinatology

The Australian and New Zealand Journal of Obstetrics and Gynaecology

BJOG: An international journal of obstetrics and gynecology

Diabetic Medicine

Diabetes

Diabetes Care

Diabetes Research and Clinical Practice

European Journal of Obstetrics & Gynecology and Reproductive Biology

International Journal of Gynecology & Obstetrics

Obstetrics & Gynecology