# Appendix A: Technical Experts and Peer Reviewers

- Donald R. Coustan, M.D.
- Chace/Joukowsky Professor and Chair
- Department of Obstetrics and Gynecology
- Warren Alpert Medical School of Brown University
- Chair of Obstetrics and Gynecology
- Women and Infants Hospital of Rhode Island
- Providence, RI

- Richard Hellman, M.D.
- Clinical Professor of Medicine
- University of Missouri - Kansas City School of Medicine
- Kansas City, MO

- Jean M. Lawrence, Sc.D., M.P.H.
- Research Scientist II/Epidemiologist
- Research and Evaluation
- Kaiser Permanente Southern California
- Pasadena, CA

- Troy Flint Porter, M.D.
- University of Utah School of Medicine and Intermountain Health Care
- Salt Lake City, UT

- Samuel F. Posner, Ph.D.
- Centers for Disease Control and Prevention
- Atlanta, GA

- E. Albert Reece, M.D., Ph.D., M.B.A.
- Dean and Vice President for Medical Affairs
- University of Maryland School of Medicine
- Baltimore, MD

- Caroline Signore, M.D., M.P.H.
- Medical Officer, Obstetrics
- Program Scientist, PASS Network
- Pregnancy and Perinatology Branch
- National Institute of Child Health and Human Development
- Bethesda, MD