# List of Abbreviations

ACOG | American College of Obstetricians and Gynecologists
ADA | American Diabetes Association
AHRQ | Agency for Healthcare Research and Quality
BMI | Body mass index
CC | Concurrent control group
CD | Cesarean delivery
CENTRAL | Central Register of Controlled Trials
CI | Confidence interval
CINAHL | Cumulative Index to Nursing and Allied Health Literature
CPD | Cephalopelvic disproportion
CRP | C-reactive protein
dL | Deciliter
EFW | Estimated fetal weight
EPC | Evidence-based Practice Center
FBG | Fasting blood glucose
FN | False negative
FP | False positive
gm | Grams
GAD | Glutamic acid decarboxylase
GCT | Glucose challenge test
Gestational diabetes | Gestational diabetes mellitus
HAPO | Hyperglycemia and Adverse Pregnancy Outcome
HDL | High-density lipoprotein
hr | Hour
IA-2 | Insulinoma antigen-2
IGT | Impaired glucose tolerance
IU | International units
kg | Kilograms
KQ | Key Question
LDL | Low-density lipoprotein
LGA | Large for gestational age
L/S ratio | Lecithin-to-sphingomyelin
MeSH | Medical subject headings
mg | milligrams
MiG | Metformin in Gestational Diabetes
MOOSE | Meta-analysis of Observational Studies in Epidemiology
NDDG | National Diabetes Data Group
NICU | Neonatal intensive care unit admissions
NPH | Neutral Protamine Hagedom
OGTT | Oral glucose tolerance test
OR | Odds ratio
PCOS | Polycystic ovarian syndrome
PDF | Portable document format
PPG | Postprandial glucose
RCT | Randomized controlled trials
RDS | Respiratory distress syndrome
RH | Relative hazard
RR | Relative risk
SD | Standard deviation
SE | Standard error
SGA | Small for gestational age
STARD | Standards for Reporting of Diagnostic Accuracy
STROBE | Standards for Reporting of Observational Studies
TN | True negative
TP | True positive
Type 2 diabetes | Type 2 diabetes mellitus
US | Ultrasound
WHO | World Health Organization