# References

1 Feig DS, Palda VA. Type 2 diabetes in pregnancy: a growing concern. Lancet. 2002;359(9318):1690-2. [pmid: 12020549].
2 Beckles GLA, Thompson-Reid PE editors. Diabetes and Women's Health Across the Life Stages: A Public Health Perspective. Atlanta: U.S. Department of Health and Human Services, Centers for Disease Control and Prevention, National Center for Chronic Disease Prevention and Health Promotion, Division of Diabetes Translation, 2001.
3 Hunt KJ, Schuller KL. The increasing prevalence of diabetes in pregnancy. Obstet Gynecol Clin North Am 2007; 34(2):173–99, vii.
4 Ferrara A, Hedderson MM, Quesenberry CP, Selby JV. Prevalence of gestational diabetes mellitus detected by the national diabetes data group or the Carpenter and Coustan plasma glucose thresholds. Diabetes Care. 2002;25(9):1625-30. [pmid: 12196438].
5 Rosenberg TJ, Garbers S, Lipkind H, Chiasson MA. Maternal obesity and diabetes as risk factors for adverse pregnancy outcomes: differences among 4 racial/ethnic groups. Am J Public Health. 2005;95(9):1545-51. [pmid: 16118366].
6 Kim C, Newton KM, Knopp RH. Gestational diabetes and the incidence of type 2 diabetes: a systematic review. Diabetes Care. 2002;25(10):1862-8. [pmid: 12351492].
7 ACOG Practice Bulletin. Clinical management guidelines for obstetrician-gynecologists. Number 30, September 2001 (replaces Technical Bulletin Number 200, December 1994). Gestational diabetes. Obstet Gynecol 2001; 98(3):525–38.
8 Homko CJ, Reece EA. Insulins and oral hypoglycemic agents in pregnancy. J Matern Fetal Neonatal Med. 2006;19(11):679-86. [pmid: 17127490].
9 Homko CJ, Sivan E, Reece AE. Is there a role for oral antihyperglycemics in gestational diabetes and type 2 diabetes during pregnancy?. Treat Endocrinol. 2004;3(3):133-9. [pmid: 16026109].
10 Langer O. Oral hypoglycemic agents in pregnancy: their time has come. J Matern Fetal Neonatal Med. 2002;12(6):376-83. [pmid: 12683647].
11 Sahin Y, Yirmibes U, Kelestimur F, Aygen E. The effects of metformin on insulin resistance, clomiphene-induced ovulation and pregnancy rates in women with polycystic ovary syndrome. Eur J Obstet Gynecol Reprod Biol. 2004;113(2):214-20. [pmid: 15063963].
12 Tuffnell DJ, West J, Walkinshaw SA. Treatments for gestational diabetes and impaired glucose tolerance in pregnancy. Cochrane Database Syst Rev 2003; (3):CD003395.
13 Gestational diabetes mellitus. Diabetes Care 2004; 27 Suppl 1:S88–90.
14 Soares AL, Sousa Mde O, Dusse LM, et al. Type 2 diabetes: assessment of endothelial lesion and fibrinolytic system markers. Blood Coagul Fibrinolysis. 2007;18(5):395-9. [pmid: 17581312].
15 Wierzbicki AS. Homocysteine and cardiovascular disease: a review of the evidence. Diab Vasc Dis Res. 2007;4(2):143-50. [pmid: 17654449].
16 Vigo A, Duncan BB, Schmidt MI, et al. Glutamic acid decarboxylase antibodies are indicators of the course, but not of the onset, of diabetes in middle-aged adults: the Atherosclerosis Risk in Communities Study. Braz J Med Biol Res. 2007;40(7):933-41. [pmid: 17653446].
17 Report of the Expert Committee on the Diagnosis and Classification of Diabetes Mellitus. Diabetes Care 1997; 20(7):1183–97.
18 Metzger BE, Coustan DR. Summary and recommendations of the Fourth International Workshop-Conference on Gestational Diabetes Mellitus. The Organizing Committee. Diabetes Care. 1998;21(Suppl 2):B161-7. [pmid: 9704245].
19 Smirnakis KV, Chasan-Taber L, Wolf M, Markenson G, Ecker JL, Thadhani R. Postpartum diabetes screening in women with a history of gestational diabetes. Obstet Gynecol. 2005;106(6):1297-303. [pmid: 16319255].
20 Clark HD, van Walraven C, Code C, Karovitch A, Keely E. Did publication of a clinical practice guideline recommendation to screen for type 2 diabetes in women with gestational diabetes change practice?. Diabetes Care. 2003;26(2):265-8. [pmid: 12547846].
21 Berlin JA. Does blinding of readers affect the results of meta-analyses? University of Pennsylvania Meta-analysis Blinding Study Group. Lancet. 1997;350(9072):185-6. [pmid: 9250191].
22 Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. 1996;17(1):1-12. [pmid: 8721797].
23 Altman, D, Egger, M, Pocock, S, Vandenbrouke, JP, von Elm, E. Strengthening the reporting of observational epidemiological studies. STROBE Statement: Checklist of Essential Items Version 3 [Web Page]. September 2005; Available at http://www.strobe-statement.org/Checkliste.html.
24 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: the STARD initiative. Fam Pract. 2004;21(1):4-10. [pmid: 14760036].
25 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
26 Higgins JP, Thompson SG, Deeks JJ, Altman DG. Measuring inconsistency in meta-analyses. BMJ. 2003;327(7414):557-60. [pmid: 12958120].
27 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations. BMJ. 2004;328(7454):1490. [pmid: 15205295].
28 Yogev Y, Langer O. Pregnancy outcome in obese and morbidly obese gestational diabetic women. Eur J Obstet Gynecol Reprod Biol 2007.
29 Gabbe SG, Graves CR. Management of diabetes mellitus complicating pregnancy. Obstet Gynecol. 2003;102(4):857-68. [pmid: 14551019].
30 Thompson DJ, Porter KB, Gunnells DJ, Wagner PC, Spinnato JA. Prophylactic insulin in the management of gestational diabetes. Obstet Gynecol. 1990;75(6):960-4. [pmid: 2188182].
31 Poyhonen-Alho M, Teramo K, Kaaja R. Treatment of gestational diabetes with short- or long-acting insulin and neonatal outcome: a pilot study. Acta Obstet Gynecol Scand. 2002;81(3):258-9. [pmid: 11966484].
32 Langer O, Conway DL, Berkus MD, Xenakis EM, Gonzales O. A comparison of glyburide and insulin in women with gestational diabetes mellitus. N Engl J Med. 2000;343(16):1134-8. [pmid: 11036118].
33 Anjalakshi C, Balaji V, Balaji MS, Seshiah V. A prospective study comparing insulin and glibenclamide in gestational diabetes mellitus in Asian Indian women. Diabetes Res Clin Pract 2006.
34 Mecacci F, Carignani L, Cioni R, et al. Maternal metabolic control and perinatal outcome in women with gestational diabetes treated with regular or lispro insulin: comparison with non-diabetic pregnant women. Eur J Obstet Gynecol Reprod Biol. 2003;111(1):19-24. [pmid: 14557006].
35 Nachum Z, Ben-Shlomo I, Weiner E, Shalev E. Twice daily versus four times daily insulin dose regimens for diabetes in pregnancy: randomised controlled trial. BMJ. 1999;319(7219):1223-7. [pmid: 10550081].
36 Jovanovic L, Ilic S, Pettitt DJ, et al. Metabolic and immunologic effects of insulin lispro in gestational diabetes. Diabetes Care. 1999;22(9):1422-7. [pmid: 10480503].
37 Bertini AM, Silva JC, Taborda W, et al. Perinatal outcomes and the use of oral hypoglycemic agents. J Perinat Med. 2005;33(6):519-23. [pmid: 16318615].
38 Gloria-Bottini F, Bottini E, Lucarini N, Palmarino R. Further observations on the relationship between adenosine deaminase and body mass. Metabolism. 1999;48(10):1336. [pmid: 10535401].
39 Simmons D, Walters BN, Rowan JA, McIntyre HD. Metformin therapy and diabetes in pregnancy. Med J Aust. 2004;180(9):462-4. [pmid: 15115425].
40 Glueck CJ, Phillips H, Cameron D, Sieve-Smith L, Wang P. Continuing metformin throughout pregnancy in women with polycystic ovary syndrome appears to safely reduce first-trimester spontaneous abortion: a pilot study. Fertil Steril. 2001;75(1):46-52. [pmid: 11163815].
41 Jakubowicz DJ, Iuorno MJ, Jakubowicz S, Roberts KA, Nestler JE. Effects of metformin on early pregnancy loss in the polycystic ovary syndrome. J Clin Endocrinol Metab. 2002;87(2):524-9. [pmid: 11836280].
42 Glueck CJ, Wang P, Kobayashi S, Phillips H, Sieve-Smith L. Metformin therapy throughout pregnancy reduces the development of gestational diabetes in women with polycystic ovary syndrome. Fertil Steril. 2002;77(3):520-5. [pmid: 11872206].
43 Glueck CJ, Wang P, Goldenberg N, Sieve-Smith L. Pregnancy outcomes among women with polycystic ovary syndrome treated with metformin. Hum Reprod. 2002;17(11):2858-64. [pmid: 12407039].
44 Rowan J. A Trial in Progress: Gestational Diabetes. Diabetes Care. 2007;30(S2):S214-9. [pmid: 17596475].
45 Chmait R, Dinise T, Moore T. Prospective observational study to establish predictors of glyburide success in women with gestational diabetes mellitus. J Perinatol. 2004;24(10):617-22. [pmid: 15152273].
46 Yogev Y, Ben-Haroush A, Chen R, Rosenn B, Hod M, Langer O. Undiagnosed asymptomatic hypoglycemia: diet, insulin, and glyburide for gestational diabetic pregnancy. Obstet Gynecol. 2004;104(1):88-93. [pmid: 15229005].
47 Conway DL, Gonzales O, Skiver D. Use of glyburide for the treatment of gestational diabetes: the San Antonio experience. J Matern Fetal Neonatal Med. 2004;15(1):51-5. [pmid: 15101612].
48 Jacobson GF, Ramos GA, Ching JY, Kirby RS, Ferrara A, Field DR. Comparison of glyburide and insulin for the management of gestational diabetes in a large managed care organization. Am J Obstet Gynecol. 2005;193(1):118-24. [pmid: 16021069].
49 Rochon M, Rand L, Roth L, Gaddipati S. Glyburide for the management of gestational diabetes: risk factors predictive of failure and associated pregnancy outcomes. Am J Obstet Gynecol. 2006;195(4):1090-4. [pmid: 17000241].
50 The Hyperglycemia and Adverse Pregnancy Outcome (HAPO) Study. Int J Gynaecol Obstet 2002; 78(1):69–77.
51 American Diabetes Association News Release. Fetus at risk at lower levels of maternal blood glucose than thought. [Web Page]. 22 June 2007; Available at http://www.diabetes.org/uedocuments/pr-fetus-risk-lower-glucose-062207.pdf. (Accessed 22 October 2007).
52 Marchiano D, Elkousy M, Stevens E, Peipert J, Macones G. Diet-controlled gestational diabetes mellitus does not influence the success rates for vaginal birth after cesarean delivery. Am J Obstet Gynecol. 2004;190(3):790-6. [pmid: 15042016].
53 Conway DL, Langer O. Elective delivery of infants with macrosomia in diabetic women: reduced shoulder dystocia versus increased cesarean deliveries. Am J Obstet Gynecol. 1998;178(5):922-5. [pmid: 9609560].
54 Keller JD, Lopez-Zeno JA, Dooley SL, Socol ML. Shoulder dystocia and birth trauma in gestational diabetes: a five-year experience. Am J Obstet Gynecol. 1991;165(4 Pt 1):928-30. [pmid: 1951556].
55 Kjos SL, Henry OA, Montoro M, Buchanan TA, Mestman JH. Insulin-requiring diabetes in pregnancy: a randomized trial of active induction of labor and expectant management. Am J Obstet Gynecol. 1993;169(3):611-5. [pmid: 8372870].
56 Rayburn WF, Sokkary N, Clokey DE, Moore LE, Curet LB. Consequences of routine delivery at 38 weeks for A-2 gestational diabetes. J Matern Fetal Neonatal Med. 2005;18(5):333-7. [pmid: 16390794].
57 Lurie S, Matzkel A, Weissman A, Gotlibe Z, Friedman A. Outcome of pregnancy in class A1 and A2 gestational diabetic patients delivered beyond 40 weeks' gestation. Am J Perinatol. 1992;9(56):484-8. [pmid: 1418162].
58 Lurie S, Insler V, Hagay ZJ. Induction of labor at 38 to 39 weeks of gestation reduces the incidence of shoulder dystocia in gestational diabetic patients class A2. Am J Perinatol. 1996;13(5):293-6. [pmid: 8863948].
59 Peled Y, Perri T, Chen R, Pardo J, Bar J, Hod M. Gestational diabetes mellitus—implications of different treatment protocols. J Pediatr Endocrinol Metab. 2004;17(6):847-52. [pmid: 15270402].
60 Cheung NW, Helmink D. Gestational diabetes: the significance of persistent fasting hyperglycemia for the subsequent development of diabetes mellitus. J Diabetes Complications. 2006;20(1):21-5. [pmid: 16389163].
61 Cho NH, Lim S, Jang HC, Park HK, Metzger BE. Elevated homocysteine as a risk factor for the development of diabetes in women with a previous history of gestational diabetes mellitus: a 4-year prospective study. Diabetes Care. 2005;28(11):2750-5. [pmid: 16249551].
62 Cho NH, Jang HC, Park HK, Cho YW. Waist circumference is the key risk factor for diabetes in Korean women with history of gestational diabetes. Diabetes Res Clin Pract. 2006;71(2):177-83. [pmid: 16054264].
63 Jang HC, Yim CH, Han KO, et al. Gestational diabetes mellitus in Korea: prevalence and prediction of glucose intolerance at early postpartum. Diabetes Res Clin Pract. 2003;61(2):117-24. [pmid: 12951280].
64 Xiang AH, Kawakubo M, Kjos SL, Buchanan TA. Long-acting injectable progestin contraception and risk of type 2 diabetes in Latino women with prior gestational diabetes mellitus. Diabetes Care. 2006;29(3):613-7. [pmid: 16505515].
65 Dacus JV, Meyer NL, Muram D, Stilson R, Phipps P, Sibai BM. Gestational diabetes: postpartum glucose tolerance testing. Am J Obstet Gynecol. 1994;171(4):927-31. [pmid: 7943102].
66 Lobner K, Knopff A, Baumgarten A, et al. Predictors of postpartum diabetes in women with gestational diabetes mellitus. Diabetes. 2006;55(3):792-7. [pmid: 16505245].
67 Metzger BE, Cho NH, Roston SM, Radvany R. Prepregnancy weight and antepartum insulin secretion predict glucose tolerance five years after gestational diabetes mellitus. Diabetes Care. 1993;16(12):1598-605. [pmid: 8299456].
68 Kjos SL, Peters RK, Xiang A, Henry OA, Montoro M, Buchanan TA. Predicting future diabetes in Latino women with gestational diabetes. Utility of early postpartum glucose tolerance testing. Diabetes. 1995;44(5):586-91. [pmid: 7729620].
69 Kjos SL, Peters RK, Xiang A, Thomas D, Schaefer U, Buchanan TA. Contraception and the risk of type 2 diabetes mellitus in Latina women with prior gestational diabetes mellitus. JAMA. 1998;280(6):533-8. [pmid: 9707143].
70 Schaefer-Graf UM, Buchanan TA, Xiang AH, Peters RK, Kjos SL. Clinical predictors for a high risk for the development of diabetes mellitus in the early puerperium in women with recent gestational diabetes mellitus. Am J Obstet Gynecol. 2002;186(4):751-6. [pmid: 11967502].
71 Steinhart JR, Sugarman JR, Connell FA. Gestational diabetes is a herald of NIDDM in Navajo women. High rate of abnormal glucose tolerance after GDM. Diabetes Care. 1997;20(6):943-7. [pmid: 9167104].
72 Peters RK, Kjos SL, Xiang A, Buchanan TA. Long-term diabetogenic effect of single pregnancy in women with previous gestational diabetes mellitus. Lancet. 1996;347(8996):227-30. [pmid: 8551882].
73 Pallardo F, Herranz L, Garcia-Ingelmo T, et al. Early postpartum metabolic assessment in women with prior gestational diabetes. Diabetes Care. 1999;22(7):1053-8. [pmid: 10388966].
74 Buchanan TA, Xiang AH, Kjos SL, Trigo E, Lee WP, Peters RK. Antepartum predictors of the development of type 2 diabetes in Latino women 11–26 months after pregnancies complicated by gestational diabetes. Diabetes. 1999;48(12):2430-6. [pmid: 10580433].
75 Buchanan TA, Xiang A, Kjos SL, et al. Gestational diabetes: antepartum characteristics that predict postpartum glucose intolerance and type 2 diabetes in Latino women. Diabetes. 1998;47(8):1302-10. [pmid: 9703332].
76 Xiang AH, Wang C, Peters RK, Trigo E, Kjos SL, Buchanan TA. Coordinate changes in plasma glucose and pancreatic beta-cell function in Latino women at high risk for type 2 diabetes. Diabetes. 2006;55(4):1074-9. [pmid: 16567531].
77 Kousta E, Efstathiadou Z, Lawrence NJ, et al. The impact of ethnicity on glucose regulation and the metabolic syndrome following gestational diabetes. Diabetologia. 2006;49(1):36-40. [pmid: 16341688].
78 Pallardo LF, Herranz L, Martin-Vaquero P, Garcia-Ingelmo T, Grande C, Janez M. Impaired fasting glucose and impaired glucose tolerance in women with prior gestational diabetes are associated with a different cardiovascular profile. Diabetes Care. 2003;26(8):2318-22. [pmid: 12882855].
79 Linne Y, Barkeling B, Rossner S. Natural course of gestational diabetes mellitus: long term follow up of women in the SPAWN study. BJOG. 2002;109(11):1227-31. [pmid: 12452459].
80 Dalfra MG, Lapolla A, Masin M, et al. Antepartum and early postpartum predictors of type 2 diabetes development in women with gestational diabetes mellitus. Diabetes Metab. 2001;27(6):675-80. [pmid: 11852376].
81 Bian X, Gao P, Xiong X, Xu H, Qian M, Liu S. Risk factors for development of diabetes mellitus in women with a history of gestational diabetes mellitus. Chin Med J (Engl). 2000;113(8):759-62. [pmid: 11776065].
82 Bartha JL, Martinez-del-Fresno P, Comino-Delgado R. Postpartum metabolism and autoantibody markers in women with gestational diabetes mellitus diagnosed in early pregnancy. Am J Obstet Gynecol. 2001;184(5):965-70. [pmid: 11303206].
83 Greenberg LR, Moore TR, Murphy H. Gestational diabetes mellitus: antenatal variables as predictors of postpartum glucose intolerance. Obstet Gynecol. 1995;86(1):97-101. [pmid: 7784031].
84 Kjos SL, Henry O, Lee RM, Buchanan TA, Mishell DR Jr. The effect of lactation on glucose and lipid metabolism in women with recent gestational diabetes. Obstet Gynecol. 1993;82(3):451-5. [pmid: 8355952].
85 Kjos SL, Shoupe D, Douyan S, et al. Effect of low-dose oral contraceptives on carbohydrate and lipid metabolism in women with recent gestational diabetes: results of a controlled, randomized, prospective study. Am J Obstet Gynecol. 1990;163(6 Pt 1):1822-7. [pmid: 2256489].
86 Roberts AB, Pattison NS. Pregnancy in women with diabetes mellitus, twenty years experience: 1968-1987. N Z Med J. 1990;103(889):211-3. [pmid: 2342692].
87 Ali Z, Alexis SD. Occurrence of diabetes mellitus after gestational diabetes mellitus in Trinidad. Diabetes Care. 1990;13(5):527-9. [pmid: 2351031].
88 The effect of intensive treatment of diabetes on the development and progression of long-term complications in insulin-dependent diabetes mellitus. The Diabetes Control and Complications Trial Research Group. N Engl J Med 1993; 329(14):977–86.
89 Kim C, Tabaei BP, Burke R, et al. Missed opportunities for type 2 diabetes mellitus screening among women with a history of gestational diabetes mellitus. Am J Public Health. 2006;96(9):1643-8. [pmid: 16873752].
90 Kim C, Herman WH, Vijan S. Efficacy and cost of postpartum screening strategies for diabetes among women with histories of gestational diabetes mellitus. Diabetes Care. 2007;30(5):1102-6. [pmid: 17322480].
91 Classification and diagnosis of diabetes mellitus and other categories of glucose intolerance. National Diabetes Data Group. Diabetes 1979; 28(12):1039–57.
92 World Health Organization. Diabetes Mellitus: Report of a WHO Study Group. Technical Report Series No. 727 edition. Geneva: World Health Organization, 1985.
93 Definition, diagnosis, and classification of diabetes mellitus and its complications. Geneva: World Health Organization, 1999.
94 Reinblatt SL, Morin L, Meltzer SJ. The importance of a postpartum 75 g oral glucose tolerance test in women with gestational diabetes. J Obstet Gynaecol Can. 2006;28(8):690-4. [pmid: 17022908].
95 Agarwal MM, Punnose J, Dhatt GS. Gestational diabetes: implications of variation in post-partum follow-up criteria. Eur J Obstet Gynecol Reprod Biol. 2004;113(2):149-53. [pmid: 15063951].
96 Holt RI, Goddard JR, Clarke P, Coleman MA. A postnatal fasting plasma glucose is useful in determining which women with gestational diabetes should undergo a postnatal oral glucose tolerance test. Diabet Med. 2003;20(7):594-8. [pmid: 12823243].
97 Conway DL, Langer O. Effects of new criteria for type 2 diabetes on the rate of postpartum glucose intolerance in women with gestational diabetes. Am J Obstet Gynecol. 1999;181(3):610-4. [pmid: 10486471].
98 Cypryk K, Czupryniak L, Wilczynski J, Lewinski A. Diabetes screening after gestational diabetes mellitus: poor performance of fasting plasma glucose. Acta Diabetol. 2004;41(1):5-8. [pmid: 15057547].
99 Jacob Reichelt AA, Ferraz TM, Rocha Oppermann ML, et al. Detecting glucose intolerance after gestational diabetes: inadequacy of fasting glucose alone and risk associated with gestational diabetes and second trimester waist-hip ratio. Diabetologia. 2002;45(3):455-7. [pmid: 11914756].
100 Costa A, Carmona F, Martinez-Roman S, Quinto L, Levy I, Conget I. Post-partum reclassification of glucose tolerance in women previously diagnosed with gestational diabetes mellitus. Diabet Med. 2000;17(8):595-8. [pmid: 11073181].
101 Kousta E, Lawrence NJ, Penny A, et al. Implications of new diagnostic criteria for abnormal glucose homeostasis in women with previous gestational diabetes. Diabetes Care. 1999;22(6):933-7. [pmid: 10372245].
102 Schmidt MI, Duncan BB, Reichelt AJ, et al. Gestational diabetes mellitus diagnosed with a 2-h 75-g oral glucose tolerance test and adverse pregnancy outcomes. Diabetes Care. 2001;24(7):1151-5. [pmid: 11423494].
103 Brown LD, Cai TT, DasGupta A. Interval estimation for a binomial proportion. Statistical Science. 2001;16:101-33.
104 Corcoy R, Garcia-Patterson A, Albareda M, de Leiva A. Poor performance of American Diabetes Association criteria in women with gestational diabetes. Diabetes Care. 2000;23(3):430-1. [pmid: 10868888].
105 American Diabetes Association. Screening for Type 2 Diabetes. Diabetes Care. 2003;26(Suppl 1):S21-S24. [pmid: 12502615].
106 Ramachandran A, Snehalatha C, Yamuna A, Mary S, Ping Z. Cost Effectiveness of the Interventions in the Primary Prevention of Diabetes among Asian Indians: Within trial results of the Indian Diabetes Prevention Programme (IDPP). Diabetes Care 2007.
107 Langer O, Yogev Y, Xenakis EM, Rosenn B. Insulin and glyburide therapy: dosage, severity level of gestational diabetes, and pregnancy outcome. Am J Obstet Gynecol. 2005;192(1):134-9. [pmid: 15672015].