# Introduction

The American College of Obstetricians and Gynecologists (ACOG) has requested an evidence report from the Agency for Healthcare Research and Quality (AHRQ) through the Evidence-based Practice Center program (EPC) to systematically and critically examine the literature on specific aspects of the management of gestational diabetes mellitus (gestational diabetes). With the ongoing increase in obesity and sedentary lifestyles, the prevalence of diabetes mellitus among reproductive-aged women is rising, both globally and in the United States.^1^ There are currently 1.85 million reproductive-aged women in the United States with gestational diabetes, type 1 or type 2 diabetes mellitus (type 2 diabetes), or glucose intolerance.^2^ Gestational diabetes, the most common medical complication of pregnancy, is defined as carbohydrate intolerance of variable degree, with an onset or first recognition occurring during pregnancy. Population-based studies estimate that gestational diabetes affects about 200,000 (7 percent) of the over 4 million births occurring annually in the United States and is associated with both maternal and neonatal complications.^3^–^5^ Furthermore, women with gestational diabetes are at high risk for future diabetes; 15 to 60 percent will develop type 2 diabetes mellitus within 5 to 15 years of delivery.^6^ Therefore, the diagnosis and subsequent management of gestational diabetes after delivery has important implications for the prevention of type 2 diabetes. A systematic review of evidence to guide decisions about glucose management, labor management, postpartum risk assessment, and screening of women with gestational diabetes would be useful for clinicians and public health officials.

In an effort to promote maternal wellbeing and avoid adverse neonatal outcomes, such as macrosomia, birth trauma, and neonatal hypoglycemia, clinical recommendations have been developed by the ACOG^7^ and the American Diabetes Association (ADA) for the obstetrical management of gestational diabetes. The guidelines emphasize the importance of glucose control to minimize the risk of macrosomia and its associated complications. When dietary management fails to achieve adequate glucose control, an anti-hyperglycemic medication should be used. Traditionally, insulin has been considered the gold standard for management because of the ability to achieve tight maternal glucose control without the risk of transfer of insulin across the placenta.^8^ However, an oral diabetes medication (i.e., glyburide) is being used increasingly in women with gestational diabetes despite the lack of approval by the Food and Drug Administration for this indication.^8^–^10^ Metformin is currently used in the non-pregnant woman with polycystic ovarian syndrome (PCOS) to treat insulin resistance and normalize ovulation.^11^ Metformin use in women with gestational diabetes is still in the experimental stages. Given the increasing use of different medications for gestational diabetes, it is time for a critical appraisal of the literature regarding the potential benefits and harms associated with the medications that can be used for the treatment of gestational diabetes.

To date, the evidence has been somewhat limited regarding the comparative effectiveness and safety of oral diabetes agents and insulin preparations for women with gestational diabetes. The Cochrane Collaboration has conducted a review of randomized clinical trials comparing the effects of alternative management strategies (e.g., dietary management, insulin, or an oral diabetes agent) in women with impaired glucose tolerance or gestational diabetes.^12^ The final analysis included three trials involving women with impaired glucose tolerance, but no trials involving women with gestational diabetes. No statistically significant differences were found in terms of cesarean delivery rates, neonatal intensive care unit admissions, or large-for-gestational age (LGA; weight greater than 90th percentile) infants among women with impaired glucose tolerance undergoing intensive treatment with insulin, as compared to those receiving dietary advice alone. Further review is needed to assess the evidence now available on the value of medical therapies for glucose control in gestational diabetes. In the current report, one of our goals was to synthesize current knowledge regarding the medical treatment benefits and harms associated with the metabolic management of gestational diabetes, by comparing insulin therapy to oral diabetes medications, including the sulfonylureas and metformin. Our maternal and neonatal outcomes of interest were chosen on the basis of established measures of maternal and infant morbidity and guidance by our team of technical experts, as described in the Methods chapter.

Both the ACOG and the ADA have provided guidelines for labor management of pregnancies complicated by gestational diabetes. The ACOG states that primary cesarean delivery may be indicated in women with gestational diabetes whose estimated fetal weight (EFW) is 4,500 grams (gm) or greater.^7^ The ADA recommends delivery during the 38th week, unless obstetric considerations dictate alternative management.^13^ Many institutions have implemented protocols for labor management of women with gestational diabetes, based largely on anecdotal or individual institutional experience. Variations in clinical management continue because patients and health care providers have differing perceptions of the potential benefits and risks of different management strategies. Neither health care providers nor patients are armed with the knowledge necessary to adequately weigh the potential benefits and harms associated with these strategies. The lack of consensus has led to controversy regarding best practices for labor management. Evidence relating to labor management can provide valuable epidemiological evidence to clinicians in daily practice as well as to professional organizations that seek to make clinical policy recommendations about the optimal delivery of obstetrical care to women with gestational diabetes.

In this report, we have systematically reviewed and summarized the available literature on outcomes associated with a range of labor management strategies, including elective induction of labor, elective cesarean delivery, and expectant management of labor. For the purposes of this report, we refer to “elective” cesarean delivery as a procedure performed after discussion between the provider and patient with the goal of avoiding adverse neonatal outcomes that occur more often in diabetic pregnancy, such as shoulder dystocia, nerve palsy, or fracture. We have also reviewed the evidence regarding the effect of gestational age and EFW on maternal and neonatal outcomes in pregnancies complicated by gestational diabetes.

There is growing interest in the effect of childbearing on the development of chronic medical conditions, including type 2 diabetes. Many studies have examined traditional risk factors for type 2 diabetes, including age, race/ethnicity, and a family history of type 2 diabetes. However, no review to date has systematically examined risk factors for type 2 diabetes in women with a history of gestational diabetes. Such a review is needed and should cover the available data on metabolic or hormonal risk factors in this population as well as emerging data on other risk factors such as homocysteine levels^14^ ^15^ and glutamic acid decarboxylase (GAD) antibodies.^16^ A review of this body of evidence could assist policymakers in the development of guidelines targeted at primary prevention of type 2 diabetes. We have therefore systematically reviewed the evidence on risk factors for type 2 diabetes in women with gestational diabetes, assessing the magnitude of individual risk factors and study quality.

Because women with gestational diabetes are at high risk for future diabetes, postpartum testing is crucial for early diagnosis of type 2 diabetes and the prevention or delay of onset of diabetic complications. The ACOG recognizes the increased risk of diabetes in women with gestational diabetes but offers no standard recommendation for postpartum testing.^7^ The ADA recommends postpartum screening at 6 weeks postpartum using either a fasting blood glucose (FBG) or an oral glucose tolerance test (OGTT).^13^ ^17^ Women with a normal result should be reassessed every 3 years. Women with impaired fasting glucose or impaired glucose tolerance should receive annual testing. The 4th International Workshop on Gestational Diabetes has recommended that postpartum glucose testing be performed at 6 to 12 weeks postpartum.^18^

Despite the general recommendation for postpartum screening, no consensus exists regarding the overall performance characteristics of the OGTT or FBG in the postpartum period or in women with a history of gestational diabetes. Emerging data suggest that many women with gestational diabetes do not receive appropriate postpartum testing,^19^ ^20^ perhaps because of limited knowledge regarding the performance of the screening tests in postpartum women, differences in the recommendations by professional organizations, and the challenges posed by the 2- to 3-hour (hr) timeframe required for an OGTT for a busy new mother. Knowledge of the performance of the FBG in comparison to the standard OGTT could help to improve patient adherence to postpartum testing. In addition, evidence related to the sensitivity and specificity of screening tests for type 2 diabetes may inform the development of evidence-based guidelines by professional organizations, prevent provider confusion about the timing of testing, and facilitate provider adherence to recommendations for testing. We have therefore investigated the performance of currently used screening tests for type 2 diabetes of pregnancies for women with a history of gestational diabetes, assessing their sensitivity and specificity and summarizing the evidence with regard to reproducibility.

To improve the outcomes of pregnancies in women with gestational diabetes, several approaches should be considered, including: (1) novel approaches to maternal glycemic control; (2) modifications of the clinical assessment for timing and method of delivery; (3) identification of risk factors for subsequent development of type 2 diabetes; and (4) clarification of the performance characteristics of postpartum glucose screening tests. The use of oral diabetes agents and/or new insulin preparations, for example, might promote better glucose control, decrease maternal hypoglycemia, and reduce abnormal fetal growth. The adaptation of new guidelines for cesarean delivery and labor induction in women with diabetes might reduce the incidence of birth trauma or nerve damage (e.g., brachial plexus palsy). A better understanding of the efficiency of postpartum glucose screening tests and screening intervals might help to identify a greater number of reproductive-aged women who are at risk of type 2 diabetes and who could be targeted for primary prevention. For example, it is possible that screening women beyond the currently recommended time interval of 6 weeks after delivery might increase the sensitivity of diabetic screening protocols. A greater number of women could then receive counseling on lifestyle modifications (i.e., nutrition, exercise). Furthermore, among those women who screen negative for glucose intolerance after the index pregnancy, lifestyle modifications might reduce the risk of development of gestational diabetes in subsequent pregnancies.

## Conceptual Framework and Key Questions

As shown in our conceptual framework (see Figure 1), we focused our evidence review on four independent, yet interrelated, areas of clinical management. The solid lines summarize the four key questions that are the focus of our review. Key Questions 1 and 2 include maternal management prior to and at the time of delivery. Also, prior clinical studies have supported a direct association between prenatal maternal glucose management and EFW and the timing of delivery, two areas of focus in Key Question 2. The link between Key Questions 1 and 2 is reflected in the commonality of several of the maternal and neonatal outcomes. From a biological perspective, metabolic control can directly influence the effects of intrauterine weight and gestational age on clinical decisionmaking in labor management.

Figure 1. Conceptual framework for labor and postpartum management of women with gestational diabetes mellitus

Maternal outcomes of interest included maternal hypoglycemia, glycemic control, pre-eclampsia, postpartum hemorrhage, maternal weight, and cesarean delivery, representing measures of maternal morbidity and quality of care. Neonatal outcomes of interest included macrosomia, neonatal hypoglycemia, birth trauma, birth weight, and respiratory distress syndrome, representing measures of neonatal morbidity and subsequent childhood wellbeing.

In Key Question 3, we examined multiple risk factors for development of type 2 diabetes. Assessment of the literature yielded two primary categories of risk factors: traditional epidemiological factors and physiological factors. As shown in the conceptual framework, these factors may be instrumental in the development of targeted interventions for this particular population of women. In Key Question 4, we assessed the performance of screening tests in detecting type 2 diabetes in women with gestational diabetes.

Our key questions were:

1 What is the evidence for the risks and benefits of oral diabetes agents (e.g., second-generation sulfonylureas and metformin), as compared to all types of insulin, for both the mother and neonate in the treatment of women with gestational diabetes?
  a How does maternal outcome vary based on the level of glucose at the initiation of a medication?
  b How does neonatal outcome vary based on the level of glucose at the initiation of a medication?
    Maternal outcomes; - cesarean delivery; - glycemic control (FBG, 1-hr and 2-hr postprandial glucose (PPG); - hemorrhage; - hypoglycemia; - operative vaginal delivery; - perineal tears; - pre-eclampsia; - weight | Neonatal outcomes; - anoxia; - birth trauma; - birth weight; - congenital malformations; - hyperbilirubinemia; - hypoglycemia; - LGA; - macrosomia; - mortality; - neonatal intensive care admissions; - respiratory distress syndrome; - shoulder dystocia; - small for gestational age (SGA)
2 What is the evidence that elective cesarean delivery or the choice of timing of induction in women with gestational diabetes results in beneficial or harmful maternal and neonatal outcomes?
  a What is the evidence for elective cesarean delivery at term, as compared to an attempt at vaginal delivery (spontaneous or induced) at term, with regard to beneficial or harmful maternal and neonatal outcomes in gestational diabetes?
    i cesarean versus spontaneous labor and vaginal delivery
    ii cesarean versus induced labor and vaginal delivery
    iii cesarean versus any attempt at vaginal delivery at term
  b What is the evidence for labor induction at 40 weeks, as compared to labor induction at an earlier gestational age (less than 40 weeks) or spontaneous labor, with regard to beneficial or harmful maternal and neonatal outcomes in gestational diabetes?
    i labor induction at less than 40 weeks versus labor induction at 40 weeks
    ii labor induction at 40 weeks versus spontaneous labor
    iii labor induction at less than 40 weeks versus spontaneous labor
  c How is the EFW related to outcomes of management of gestational diabetes with elective cesarean delivery or the timing (i.e., gestational age range) of labor induction?
  d How is gestational age related to outcomes of management of gestational diabetes with elective cesarean delivery or the choice of timing (i.e., gestational age range) of labor induction?
    Maternal outcomes; - cesarean delivery; - hemorrhage; - infection; - operative vaginal delivery; - perineal tears | Neonatal outcomes; - anoxia; - birth trauma; - birth weight; - congenital malformations; - hyperbilirubinemia; - hypoglycemia; - LGA; - macrosomia; - mortality; - neonatal intensive care admissions; - respiratory distress syndrome; - shoulder dystocia; - SGA
3 What risk factors, including but not limited to family history, physical activity, pre-pregnancy weight, and gestational weight gain, are associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes?
4 What are the performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes after pregnancy in patients with a history of gestational diabetes? Are there differences in the performance characteristics of the test results based on subgroup analysis?

A systematic review of the evidence on labor and postpartum management of gestational diabetes can provide support for clinical guidelines, thereby arming clinicians with the knowledge necessary to provide evidenced-based, quality care to a growing population of women. For the current 200,000 pregnancies that are complicated by gestational diabetes annually in the United States, evidence-based clinical practice will be essential in promoting treatment effectiveness, evidenced-based labor management, effective assessment of risk factors for later development of type 2 diabetes in women with gestational diabetes, and efficient postpartum screening for type 2 diabetes.