# Executive Summary

## Introduction

Gestational diabetes mellitus (gestational diabetes), one of the most common medical complications of pregnancy, is defined as carbohydrate intolerance of variable degree, with an onset or first recognition occurring during pregnancy. Of the estimated 4 million births annually in the United States, gestational diabetes affects approximately 200,000 (7 percent), depending on the criteria (diagnostic test and threshold values) chosen for diagnosis. Initial diagnostic criteria for gestational diabetes were based on the ability to identify women at risk of developing type 2 diabetes, since 15 to 60 percent of women with gestational diabetes develop type 2 diabetes mellitus within 5 to 15 years of delivery. Therefore, the diagnosis and subsequent management of gestational diabetes after delivery has important implications for the prevention of type 2 diabetes. Questions remain, however, about the optimal ways to assess the postpartum risk of diabetes and to screen women for diabetes after a diagnosis of gestational diabetes has been made.

Equally important, gestational diabetes is associated with both maternal and infant complications, including maternal and neonatal hypoglycemia and complications of macrosomia, such as birth trauma and cesarean delivery. Treatment recommendations for gestational diabetes are based primarily on evidence from early trials suggesting that insulin treatment can reduce the incidence of macrosomia. To date, relatively little work has been done to synthesize more recent evidence regarding the management of maternal glucose or physicians' decisions to recommend elective labor induction or cesarean delivery in women with gestational diabetes.

Furthermore, while there is substantial literature regarding risk factors for type 2 diabetes, there has been no comprehensive review of these risk factors or the relative magnitude of their associations with type 2 diabetes. Finally, little work has been done to investigate the performance of postpartum glucose testing in women with gestational diabetes or to analyze the effect of performing the tests at different time intervals following delivery on the relative performance of current screening modalities.

Because of the broad clinical and public health policy implications of the management of women with gestational diabetes, the American College of Obstetricians and Gynecologists (ACOG) requested an evidence report from the Agency for Healthcare Research and Quality (AHRQ) through the Evidence-based Practice Center program (EPC) to systematically and critically examine the literature on specific aspects of the management of gestational diabetes. We were guided in our key questions and outcomes of interest by the ACOG, the AHRQ, and our panel of technical experts.

Our key questions were:

1 What is the evidence for the risks and benefits of oral diabetes agents (e.g., second-generation sulfonylureas and metformin), as compared to all types of insulin, for both the mother and neonate in the treatment of women with gestational diabetes?
  a How does maternal outcome vary based on the level of glucose at the initiation of a medication?
  b How does neonatal outcome vary based on the level of glucose at the initiation of a medication?
    Maternal outcomes; - cesarean delivery; - glycemic control (fasting blood glucose [FBG], 1-hour [hr] and 2-hr postprandial glucose [PPG]); - hemorrhage; - hypoglycemia; - operative vaginal delivery; - perineal tears; - pre-eclampsia; - weight | Neonatal outcomes; - anoxia; - birth trauma; - birth weight; - congenital malformations; - hyperbilirubinemia; - hypoglycemia; - large for gestational age (LGA); - macrosomia; - mortality; - neonatal intensive care admissions; - respiratory distress syndrome; - shoulder dystocia; - small for gestational age (SGA)
2 What is the evidence that elective cesarean delivery or the choice of timing of induction in women with gestational diabetes results in beneficial or harmful maternal and neonatal outcomes?
  a What is the evidence for elective cesarean delivery at term, as compared to an attempt at vaginal delivery (spontaneous or induced) at term, with regard to beneficial or harmful maternal and neonatal outcomes in gestational diabetes?
    i cesarean versus spontaneous labor and vaginal delivery
    ii cesarean versus induced labor and vaginal delivery
    iii cesarean versus any attempt at vaginal delivery at term
  b What is the evidence for labor induction at 40 weeks, as compared to labor induction at an earlier gestational age (less than 40 weeks) or spontaneous labor, with regard to beneficial or harmful maternal and neonatal outcomes in gestational diabetes?
    i labor induction at less than 40 weeks versus labor induction at 40 weeks
    ii labor induction at 40 weeks versus spontaneous labor
    iii labor induction at less than 40 weeks versus spontaneous labor
  c How is the estimated fetal weight (EFW) related to outcomes of management of gestational diabetes with elective cesarean delivery or the timing (i.e., gestational age range) of labor induction?
  d How is gestational age related to outcomes of management of gestational diabetes with elective cesarean delivery or the choice of timing (i.e., gestational age range) of labor induction?
    Maternal outcomes; - cesarean delivery; - hemorrhage; - infection; - operative vaginal delivery; - perineal tears | Neonatal outcomes; - same as Key Question 1
3 What risk factors, including but not limited to family history, physical activity, pre-pregnancy weight, and gestational weight gain, are associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes?
4 What are the performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes after pregnancy in patients with a history of gestational diabetes? Are there differences in the performance characteristics of the test results based on subgroup analysis?

## Methods

### Approach to Evaluating the Literature

We identified the primary literature on labor and postpartum management of gestational diabetes and the association with maternal and neonatal outcomes through a comprehensive search plan that included electronic and hand searching. We ran searches of the following databases for the specified periods of time: MEDLINE^®^ (1950 through January 2007), EMBASE^®^ (1974 through January 2007), The Cochrane Central Register of Controlled Trials (CENTRAL; Issue 1, 2007), and the Cumulative Index to Nursing & Allied Health Literature (CINAHL^®^; 1982 through January 2007). Hand searching for relevant citations took several forms. From our electronic search, we identified the 13 journals (see Appendix B ^a^) that were most likely to publish articles on this topic. We scanned the table of contents of each issue of these journals for relevant articles from August 2006 through January 2007. For the second form of hand searching, reviewers received eligible articles and flagged references of interest for the team to compare to the existing database.

a Appendixes cited in this report are provided electronically at: http://www.ahrq.gov/clinic/tp/gdmparttp.htm

Two independent reviewers conducted title scans in a parallel fashion. If either reviewer thought that a title was potentially eligible, its abstract was reviewed. If the abstract was deemed to meet the inclusion criteria by two reviewers, the abstract was included in our article review. Any differences of opinion were resolved by the two primary reviewers or by a third independent reviewer.

Each eligible article underwent double review by study investigators. A primary reviewer completed all data abstraction forms, and a second reviewer confirmed the first reviewer's data abstraction forms for completeness and accuracy. The reviewers assessed study quality independently. Reviewer pairs were formed to include personnel with both clinical and methodological expertise. A third reviewer re-reviewed a random sample of articles by the first two reviewers to ensure consistency in the abstraction of the articles.

### Quality Assessment

We used several study quality assessment tools, based on the study design of the articles included in the review. Our dual, independent review of article quality judged articles on several aspects of each study type's internal validity. Quality assessment of trials for Key Questions 1 and 2 was based on the Jadad criteria and included: (1) whether the study was randomized, (2) the appropriateness of the randomization scheme, (3) whether the study was blinded, (4) the appropriateness of the blinding, and (5) the description of withdrawals and drop-outs. For each trial, we created a score between 5 (high quality) and 0 (low quality). Quality assessment of observational studies for Key Questions 1, 2, and 3 was designed by selecting key elements from the Standards for Reporting of Observational Studies (STROBE) checklist for reporting observational studies. The STROBE checklist is based on the consensus of 27 participants of the Meta-analysis of Observational Studies in Epidemiology (MOOSE) group and includes recommendations for standards for individual studies with regard to the presentation of the study hypotheses, eligibility criteria, study population, power and sample size calculations, definitions of outcomes, and description of loss to followup and missing data. Quality assessment of the diagnostic test studies for Key Question 4 was designed by selecting key elements from the Standards for Reporting of Diagnostic Accuracy (STARD) Initiative and included items about reporting the sampling design, describing the lost-to-followup, reporting diagnostic accuracy, verifying positive and negative tests equally, interpreting the tests independently, reporting reproducibility, and reporting subgroup analyses.

Based on the quantity, quality, and consistency of the studies, we graded the overall body of evidence for each of the key questions using the evidence-grading scheme recommended by the GRADE Working Group.

### Analysis

We conducted meta-analyses when there were sufficient data (three or more studies) and the studies were homogeneous with respect to key variables (population characteristics, study duration, intervention/exposure/comparison tests, and length of followup). When the data were not sufficient to allow us combine the studies in a meta-analysis, we prepared a qualitative summary of the results.

## Results

### Search Results

We retrieved 11,400 unique citations from our original search. After reviewing the titles and abstracts, 552 were deemed eligible for further review, and the full articles were retrieved. A total of 45 articles were ultimately included in this review.

### Key Question 1

What is the evidence for the risks and benefits of oral diabetes agents (e.g., second-generation sulfonylureas and metformin), as compared to all types of insulin, for both the mother and neonate in the treatment of women with gestational diabetes?

a How does maternal outcome vary based on the level of glucose at the initiation of a medication?
b How does neonatal outcome vary based on the level of glucose at the initiation of a medication?

- We identified eight randomized controlled trials (RCTs) with a total of 845 participants that met our inclusion criteria for review: Three trials compared insulin to glyburide; two trials compared insulin to insulin lispro; one trial compared long-acting to short-acting insulin; one trial compared four-times-daily insulin to two-times daily insulin; and one trial compared diet to insulin.
- Two small trials and one large trial (404 women) reported no significant difference in maternal glucose control or rates of cesarean delivery between the insulin and glyburide groups.
- A meta-analysis of the three RCTs comparing insulin and glyburide showed that treatment with insulin was associated with a lower mean infant birth weight when compared to glyburide (weighted mean difference: -93 grams [gm]) (95 percent confidence interval [CI]: -191 to 5 gm), but the difference was small and not statistically significant.
- The largest trial reported no difference in the proportion of infants with hypoglycemia (9 percent with glyburide as compared to 6 percent with insulin therapy [p = 0.25]). A smaller trial reported a significantly higher percentage of infants with hypoglycemia in the glyburide group than in the insulin or acarbose groups (33 percent compared to 4 percent and 5 percent, respectively; p = 0.006).
- Four observational studies (N = 911 women) compared the effects of insulin and glyburide on maternal and neonatal outcomes.
- Due to potential selection bias, loss to followup, and the lack of any power analysis to estimate detectable effect sizes, none of the observational studies was deemed strong enough to justify a modification of the conclusions drawn from the RCTs.
- We graded the overall evidence comparing insulin and glyburide as very low.
- We identified two RCTs that compared insulin lispro to insulin. It appeared that insulin lispro might be associated with tighter maternal glucose control than regular insulin, but there were only limited data to support this conclusion.
- Both RCTs reported similar rates of cesarean delivery among women in the insulin lispro group, as compared to the insulin group.
- No evidence existed to suggest that neonatal outcomes differ between women treated with insulin lispro and those treated with regular insulin.
- We graded the strength of the evidence comparing insulin to insulin lispro as very low.
- One RCT (N = 23 women) reported that long-acting insulin was associated with a higher proportion of infants with macrosomia when compared to short-acting insulin. No difference in birth trauma or metabolic abnormalities was found, but this study was not adequately powered to detect differences in these outcomes.
- There was insufficient evidence to allow us to draw any conclusions regarding maternal outcomes.
- One RCT (N = 274 women) reported that twice-daily insulin was associated with a higher proportion of hypoglycemia (6 percent versus 1 percent; p = 0.002) and hyperbilirubinemia (21 percent versus 11 percent; p = 0.002) when compared to four-times-daily insulin. No evidence existed to suggest a difference in maternal glucose levels or cesarean delivery between twice-daily and four-times-daily use of insulin.
- We identified only one RCT (N = 95 women) that reported lower rates of macrosomia (5.9 percent versus 26.5 percent, respectively; p = 0.005) and lower infant birth weights (p = 0.002) for those using insulin plus dietary management versus those treated with diet alone.
- We graded the overall evidence regarding comparisons of diet plus insulin to diet alone as very low, given that only one small RCT met our inclusion criteria.
- We found no evidence to indicate whether the relative effect of different treatment approaches on maternal and infant outcomes varied with the level of glucose at the initiation of medical therapy.
- We expect that the ongoing Hyperglycemia and Adverse Pregnancy Outcomes (HAPO) Study, an observational study of 23,325 pregnant women, should provide data on maternal and neonatal outcomes at various maternal glucose levels and potentially indicate thresholds at which medical therapy should be initiated.
- We found no RCTs or observational studies comparing metformin to insulin in gestational diabetics that met our criteria for review. The Metformin in Gestational Diabetes (MiG) Trial is an ongoing randomized trial of over 500 women that should provide future insight into the benefits and risks of metformin use throughout pregnancy.
- There were insufficient data regarding the teratogenic effects of intrauterine exposure to metformin or its potential effect on infant growth and motor development.

### Key Question 2

What is the evidence that elective cesarean delivery or the choice of timing of induction in women with gestational diabetes results in beneficial or harmful maternal and neonatal outcomes?

- One RCT and seven observational studies evaluated two of our five maternal outcomes of interest and 11 of the 12 neonatal outcomes of interest.
- One RCT of 200 women reported that elective induction at 38 weeks of gestation, as compared to expectant management (induction at 42 weeks' gestation or if the EFW was 4,200 gm or greater), reduced infant birth weight and the rate of macrosomia but did not alter other maternal or neonatal outcomes, including the rate of cesarean delivery.
- Two observational studies of low quality also reported a reduction in infant birth weight or rates of macrosomia in women induced at 38 weeks of gestation, as compared to historical controls.
- Five additional observational studies examined the effects of various delivery management protocols, but each had serious limitations, including reliance on historical controls, no adjustment for potential confounders, or no adjustment or stratified analysis based on severity of gestational diabetes (class A1 [diet-controlled] versus class A2 [insulin-controlled]). In addition, the studies covered a wide time period (4–19 years), with no adjustment for changes in clinical practice.
- We were unable to draw firm conclusions from the limited data available.
- We graded the overall strength of the evidence as very low, given the limited number of RCTs and the serious design limitations in the conduct of the observational studies.

### Key Question 3

What risk factors, including but not limited to family history, physical activity, pre-pregnancy weight, and gestational weight gain, are associated with short-term and long-term development of type 2 diabetes following a pregnancy with gestational diabetes?

- We developed an a priori list of risk factors for type 2 diabetes, based on guidance from the AHRQ, the ACOG, and members of our technical panel, and then grouped these risk factors into nine categories:
  1 Family history of type 2 diabetes
  2 Sociodemographics
  3 Lifestyle factors
  4 Parity
  5 Pregnancy-related factors
  6 Postpartum factors
  7 Measures of anthropometry
  8 Oral contraceptives
  9 Physiological measures
- Sixteen studies evaluated at least one risk factor and reported adjusted measures of association.
- We identified 11 cohort studies that evaluated the relationship between 11 different anthropometric measures and the development of type 2 diabetes; 8 studies reported adjusted measures of association from multivariate models.
- Seven of the eight studies that evaluated anthropometric measures (pre-pregnancy body mass index [BMI], pregnancy BMI, weight, waist-to-hip ratio) using multivariate analysis reported that these measures were positively associated with the risk of developing type 2 diabetes.
- We graded the evidence on anthropometric measures and the risk of developing type 2 diabetes as moderate because of the inconsistency in the anthropometric measures used across the studies.
- We identified five studies that included family history of type 2 diabetes in the multivariate analysis, but only one study reported the actual magnitude of the association of family history with the risk of type 2 diabetes, and this association was not statistically significant (relative risk [RR] = 1.7; 95 percent CI: 0.6 to 4.6).
- We graded the evidence on family history as very low because only one study reported the actual measure of association.
- Five studies assessed age as a risk factor for developing type 2 diabetes among gestational diabetics, but only one study reported the actual measure of association; women who were 30 years of age and older at diagnosis of gestational diabetes had a higher likelihood of developing type 2 diabetes, but the relative risk was not statistically significant.
- We did not identify any studies of lifestyle behaviors that met our criteria for inclusion in this review.
- Gestational age at diagnosis of gestational diabetes was inversely associated with a higher likelihood of the development of type 2 diabetes, but the modeling of gestational age varied across studies and therefore limited our ability to synthesize the data.
- Two studies evaluated the association between the use of progesterone-only contraception or combination oral contraception (estrogen and progesterone) and the risk of developing type 2 diabetes in women with gestational diabetes. One study reported a two-fold increase in the risk of developing diabetes with the use of progestin-only oral contraceptives as compared to combination oral contraception; one study reported no increased risk in women using depo-medroxyprogesterone acetate as compared to combined oral contraceptives.
- FBG, 2-hour glucose value, and the area under the curve from the diagnostic antepartum oral glucose tolerance test (OGTT) were associated with a significantly higher risk of developing type 2 diabetes in women with gestational diabetes.

### Key Question 4

What are the performance characteristics (sensitivity, specificity, and reproducibility) of tests for diagnosing type 2 diabetes after pregnancy in patients with a history of gestational diabetes? Are there differences in the performance characteristics of the test results based on subgroup analysis?

- We identified eight studies that reported 10 evaluations of the performance of a reference test versus a comparison (screening) test for the diagnosis of type 2 diabetes in the postpartum period.
- Our review yielded three general comparisons: (1) two different diagnostic threshold values applied to the 75-gm OGTT (the World Health Organization [WHO] 1985 criterion compared with the WHO 1999 criterion), (2) FBG level greater than 7.0 mmol/L (126 mg/dL) (the American Diabetes Association [ADA] 1997) compared to the 75-gm OGTT (WHO 1999), and (3) FBG greater than 7.0 mmol/L (126 mg/dL) (ADA 1997) compared to the 75-gm OGTT (WHO 1985).
- The sensitivity for the FBG greater than 7.0 mmol/L (126 mg/dL) alone as compared with a complete OGTT using the same FBG threshold (FBG greater than 7.0 mmol/L (126 mg/dL) or a 2-hr plasma glucose level after 75-g OGTT greater than 11.1 mmol/L (200 mg/dL) varied across the three studies, ranging from 46 to 89 percent.
- With a threshold greater than 7.0 mmol/L, the FBG had high specificity when compared to the 75-gm OGTT but had highly variable sensitivity.
- No studies included in this review reported measures of reproducibility.
- We graded the strength of the evidence regarding postpartum screening for type 2 diabetes as very low because of the limited number of studies within each category of comparisons and the heterogeneity in the study populations.

## Discussion

### Conclusions

Although the overall quality of the evidence was very low, we were able to draw some conclusions regarding treatment options for maternal glucose control, the timing and method of delivery, the risk factors for the development of type 2 diabetes, and the performance characteristics of screening tests conducted in the postpartum period to identify those who have developed type 2 diabetes.

When patients ask about the effect of the use of insulin analogues or glyburide as compared to insulin, clinicians should be aware that little clinical difference has been demonstrated in the infant birth weights associated with the use of these three regimens. Clinicians should also be aware that while the use of an alternative to regular insulin is unlikely to result in any adverse maternal or infant outcomes, there were insufficient data to allow us to determine whether insulin analogues or glyburide are more efficacious than regular insulin in achieving maternal glucose targets. Also, there was no evidence supporting a difference in terms of the prevention of episodes of maternal or neonatal hypoglycemia. To date, only insulin has been approved by the Food and Drug Administration for use in gestational diabetes. Because of the limited data available, it was unclear what glucose thresholds should be used to initiate treatment with insulin, insulin analogues, or glyburide in patients who are being treated with diet alone. Furthermore, there were insufficient data regarding the potential benefits or risk of metformin use.

There was also insufficient evidence to permit us to develop guidelines for elective labor induction or cesarean delivery in women with gestational diabetes. Well-designed clinical trials are needed to provide a stronger base of evidence for the management of gestational diabetes.

Based on multivariate models, measures of obesity appeared to be the strongest risk factor for type 2 diabetes in women with gestational diabetes. We have concluded that there are insufficient data to justify recommending alternative tests to the 75-gm OGTT for the detection of type 2 diabetes in women with gestational diabetes. Further studies conducted in diverse populations and high-risk subgroups and incorporating measures of reproducibility will help to move this area of investigation toward the development of clinically acceptable testing guidelines.

## Limitations

This review has several important limitations. First, the heterogeneous nature of the studies prevented a quantitative summary of much of the data. For Key Question 1, we were able to provide a summary measure of the weighted mean difference in infant birth weight in the three RCTs comparing insulin and glyburide. However, the pooled estimate provided data on only one of several important maternal and neonatal outcomes related to medical treatment in gestational diabetics. We were unable to conduct additional analysis because the number of trials comparing similar treatments was very limited. Also, maternal and neonatal outcomes were not consistent across studies. Few of the same outcome measures were included in two or more studies, and the definitions of outcomes varied across studies. Our review of five observational studies comparing of glyburide and insulin did not alter our limited conclusions from the RCTs. We were further limited by a lack of data on the potential risk of glyburide use. We were unable to provide evidence on the potential risks and benefits of metformin because of a lack of published studies that met our inclusion criteria.

We were also unable to draw substantial conclusions from our review of seven observational studies and a single RCT on elective induction and cesarean delivery. The observational studies had serious limitations, with no adjustment for potential confounders, severity of gestational diabetes, or variation in the definitions of major outcomes. There was substantial heterogeneity in the study populations and the time periods of these observational studies.

The lack of multivariate analysis in some studies, as well as inconsistencies in the covariates included in the multivariate models of other studies, made it difficult to compare results across the 16 studies on risk factors for type 2 diabetes. We found limited evidence for the magnitude of association of traditional risk factors (sociodemographics, parity, family history) with the development of type 2 diabetes in women with gestational diabetes. We were also limited by the lack of availability of any studies on the possible relationship of lifestyle behaviors to the risk of type 2 diabetes.

Finally, heterogeneity in the study populations and the time intervals of postpartum testing made it difficult to draw firm conclusions regarding the effectiveness of postpartum glucose screening in women with a history of gestational diabetes.

## Future Research Implications

- Researchers should focus on conducting studies that will lead to the development of evidenced-based guidelines for maternal glucose control in gestational diabetes and physician recommendations for labor induction, elective cesarean, or expectant management.
- Well-designed RCTs with a priori hypotheses, power analysis, appropriate effect sizes, and intention-to-treat analysis can provide better data on treatment efficacy.
- Consistency in the definition and collection of maternal and infant outcome measures is essential to our ability to draw confident conclusions about potential benefits and harms of treatment options among women with gestational diabetes.
- The best evidence for delivery management in women with gestational diabetes will be garnered from the conduct of well-designed RCTs comparing elective induction and cesarean delivery to expectant management. Alternatively, observational studies with consistency in outcomes measures and multivariate adjustment for potential confounders can provide important, relevant information.
- Those conducting longitudinal studies of women with a history of gestational diabetes should develop and follow standard protocols for retention in an effort to improve followup rates. Future studies should collect data on pertinent covariates and adjust for relevant confounders in multivariate analysis.
- Studies measuring the sensitivity, specificity, and reproducibility of screening tests for type 2 diabetes in women with a history of gestational diabetes can help physicians in the early identification of women with type 2 diabetes and avoid potential medical complications of diabetes.
- A comparison of screening and reference tests in certain subgroups (i.e., those with a family history type 2 diabetes or prior gestational diabetes) is also warranted.
- In order to develop broadly acceptable guidelines for postpartum screening for type 2 diabetes in women with prior gestational diabetes, additional research should be conducted to assess test reproducibility as well as test performance based on varying intervals of postpartum screening.