# Acknowledgments

The Evidence-based Practice Center thanks Gabriel Lai and Haeseong Park for their assistance with article reviewing and data entry; Karen Robinson for her guidance on the search strategy; Allison Jonas for her assistance with final preparations of the report; Deborah McClellan for copy editing; and Renee Wilson and Michael Oladubu for their assistance with the study. We would also like to acknowledge our technical expert panel:

- E. Albert Reece, M.D., Ph.D., M.B.A.
- Dean & Vice President for Medical Affairs
- University of Maryland School of Medicine
- Baltimore, MD

- Richard Hellman, M.D.
- Clinical Professor of Medicine
- University of Missouri - Kansas City School of Medicine
- Kansas City, MO

- Troy Flint Porter, M.D.
- University of Utah School of Medicine and Intermountain Health Care
- Salt Lake City, UT

- Jean M. Lawrence, Sc.D., M.P.H.
- Research Scientist II/Epidemiologist
- Research and Evaluation
- Kaiser Permanente Southern California
- Pasadena, CA