# List of Acronyms/Abbreviations

ADL | Activities of daily living
AI | Anal incontinence
BMI | Body mass index
CI | Confidence interval
COPD | Chronic obstructive pulmonary disease
EMG | Electromyography
FI | Fecal incontinence
FIQL | Fecal incontinence quality of life
GI | Gastrointestinal
IBD | Inflammatory bowel disease
IBS | Irritable bowel syndrome
ICI | International consultation on incontinence
ICS | International Continence Society
LTC | Long-term care
MDS | Minimum data set
MMSE | Mini mental state examination
PPV | Positive predictive value
RCT | Randomized controlled trial
RR | Relative risk
SNRI | Serotonin norephinephine reuptake inhibitors
SSRI | Selective serotonin reuptake inhibitors
SUIQQ | Stress and urge incontinence and quality of life questionnaire
TEP | Technical expert panel
UI | Urinary incontinence
UISS | Urinary incontinence severity score