# References and Included Studies

1 Sgadari A, Topinkova E, Bjornson J, et al. Urinary incontinence in nursing home residents: a cross-national comparison. Age Ageing. Sep. 1997;26(Suppl 2):49-54. [pmid: 9464555].
2 Anger JT, Saigal CS, Pace J, et al. True prevalence of urinary incontinence among female nursing home residents. Urology. Feb. 2006;67(2):281-7. [pmid: 16461078].
3 Nelson R, Furner S, Jesudason V. Fecal incontinence in Wisconsin nursing homes: prevalence and associations. Dis Colon Rectum. Oct. 1998;41(10):1226-9. [pmid: 9788384].
4 Nelson RL, Furner SE. Risk factors for the development of fecal and urinary incontinence in Wisconsin nursing home residents. Maturitas. Sep 16. 2005;52(1):26-31. [pmid: 16143223].
5 Bliss DZ, Savik K, Harms S, et al. Prevalence and correlates of perineal dermatitis in nursing home residents. Nurs Res. Jul–Aug. 2006;55(4):243-51. [pmid: 16849976].
6 Roberts RO, Jacobsen SJ, Reilly WT, et al. Prevalence of combined fecal and urinary incontinence: a community-based study. J Am Geriatr Soc. Jul. 1999;47(7):837-41. [pmid: 10404928].
7 MacLennan AH, Taylor AW, Wilson DH, et al. The prevalence of pelvic floor disorders and their relationship to gender, age, parity and mode of delivery. Bjog. Dec. 2000;107(12):1460-70. [pmid: 11192101].
8 Anger JT, Saigal CS, Stothers L, et al. The prevalence of urinary incontinence among community dwelling men: results from the National Health and Nutrition Examination survey. J Urol. Nov. 2006;176(5):2103-8. discussion 8. [pmid: 17070268].
9 Anger JT, Saigal CS, Litwin MS. The prevalence of urinary incontinence among community dwelling adult women: results from the National Health and Nutrition Examination Survey. J Urol. Feb. 2006;175(2):601-4. [pmid: 16407004].
10 Sloss EM, Solomon DH, Shekelle PG, et al. Selecting target conditions for quality of care improvement in vulnerable older adults. J Am Geriatr Soc. Apr. 2000;48(4):363-9. [pmid: 10798460].
11 Papanicolaou S, Hunskaar S, Lose G, et al. Assessment of bothersomeness and impact on quality of life of urinary incontinence in women in France, Germany, Spain and the UK. BJU Int. Oct. 2005;96(6):831-8. [pmid: 16153212].
12 Fultz NH, Herzog AR. Self-reported social and emotional impact of urinary incontinence. J Am Geriatr Soc. Jul. 2001;49(7):892-9. [pmid: 11527480].
13 Excellence NIfHaC. Faecal Incontinence. National Collaborating Centre for Acute Care at The Royal College of Surgeons of England. Available at: http://www.nice.org.uk/page.aspx?o=389312.
14 Lose G, Fantl JA, Victor A, et al. Outcome measures for research in adult women with symptoms of lower urinary tract dysfunction. Standardization Committee of the International Continence Society. Acta Obstet Gynecol Scand. Nov. 2001;80(11):981-5. [pmid: 11703192].
15 Martin JL, Williams KS, Sutton AJ, et al. Systematic review and meta-analysis of methods of diagnostic assessment for urinary incontinence. Neurourol Urodyn. 2006;25(7):674-83. discussion 84. [pmid: 17016795].
16 Martin JL, Williams KS, Abrams KR, et al. Systematic review and evaluation of methods of assessing urinary incontinence. Health Technol Assess 2006 Feb; 10(6):1–132, iii–iv.
17 Rao SS. Diagnosis and management of fecal incontinence. American College of Gastroenterology Practice Parameters Committee. Am J Gastroenterol. Aug. 2004;99(8):1585-604. [pmid: 15307881].
18 Litwin MS, Saigal CS, National Institute of Diabetes and Digestive and Kidney Diseases (U.S.). Urologic diseases in America: interim compendium. National Institute of Diabetes & Digestive & Kidney Diseases National Institutes of Health Dept. of Health and Human Services. Available at: http://purl.access.gpo.gov/GPO/LPS69698
19 Deutekom M. Faecal incontinence: impact, treatment and diagnostic work-up. S.l.: s.n.; 2005.
20 Abrams P, Cardozo L, Khoury S, et al. Incontinence. Proceedings from the 3rd International Consultation on Incontinence. Paris, France: Health Publications, Ltd.; 2005.
21 Abrams P, Cardozo L, Khoury S, et al. Incontinence. 3rd International Consultation on Incontinence. Plymouth: Health Publications; 2005.
22 Kasper DL, Harrison TR, NetLibrary Inc. Harrison's principles of internal medicine. McGraw-Hill Medical Pub. Division [Bibliographic record display]. Available at: http://www.netLibrary.com/urlapi.asp?action=summary&v=1&bookid=149871 An electronic book accessible through the World Wide Web; click for information; http://www.netLibrary.com/urlapi.asp?msg=iGwmKofsjNse7T654jizTngP2Cm82xVuelvum762Mna+xOR+sfqPcrGXnVx1MhztuL+vMLr8hIj2?wsPEqz3ptQ3GVJKsS5mv1mtfFGEET1yrO0ZeNrR13yZwaWQ9MTIzJmV0PTNk
23 Abrams P, Cardozo L, Khoury S, et al. Incontinence. 2005 ed. Paris: Health Publications: Editions 21 distributor; 2005.
24 Madoff RD, Parker SC, Varma MG, et al. Faecal incontinence in adults. Lancet. Aug 14–20. 2004;364(9434):621-32. [pmid: 15313364].
25 Managing acute and chronic urinary incontinence [microform]. Rockville, MD; Washington, DC: U.S. Dept. of Health and Human Services Public Health Service Agency for Health Care Policy and Research; Available for sale from the G.P.O. Supt. of Docs; 1996.
26 United States Agency for Health Care Policy and Research. Urinary incontinence in adults: clinical practice guideline. Rockville, Md.: U.S. Dept. of Health and Human Services Public Health Service Agency for Health Care Policy and Research; 1992.
27 Managing acute and chronic urinary incontinence. AHCPR Urinary Incontinence in Adults Guideline Update Panel. Am Fam Physician 1996 Oct; 54(5):1661–72.
28 Palmer MH, German PS, Ouslander JG. Risk factors for urinary incontinence one year after nursing home admission. Res Nurs Health. Dec. 1991;14(6):405-12. [pmid: 1792342].
29 Aggazzotti G, Pesce F, Grassi D, et al. Prevalence of urinary incontinence among institutionalized patients: a cross-sectional epidemiologic study in a midsized city in northern Italy. Urology. Aug 1. 2000;56(2):245-9. [pmid: 10925087].
30 Adelmann PK. Prevalence and detection of urinary incontinence among older Medicaid recipients. J Health Care Poor Underserved. Feb. 2004;15(1):99-112. [pmid: 15359977].
31 Jumadilova Z, Zyczynski T, Paul B, et al. Urinary incontinence in the nursing home: resident characteristics and prevalence of drug treatment. Am J Manag Care. Jul. 2005;11(4 Suppl):S112-20. [pmid: 16161384].
32 Boyington JE, Howard DL, Carter-Edwards L, et al. Differences in resident characteristics and prevalence of urinary incontinence in nursing homes in the southeastern United States. Nurs Res. Mar–Apr. 2007;56(2):97-107. [pmid: 17356440].
33 Liu C, Andrews GR. Prevalence and incidence of urinary incontinence in the elderly: a longitudinal study in South Australia. Chin Med J (Engl). Jan. 2002;115(1):119-22. [pmid: 11930643].
34 Borrie MJ, Davidson HA. Incontinence in institutions: costs and contributing factors. Cmaj. Aug 1. 1992;147(3):322-8. [pmid: 1643598]. [pmcid: 1336202].
35 Damian J, Martin-Moreno JM, Lobo F, et al. Prevalence of urinary incontinence among Spanish older people living at home. Eur Urol. Oct. 1998;34(4):333-8. [pmid: 9748681].
36 Roe B, Doll H. Prevalence of urinary incontinence and its relationship with health status. J Clin Nurs. Mar. 2000;9(2):178-87. [pmid: 11111607].
37 Andersson G, Johansson JE, Garpenholt O, et al. Urinary incontinence—prevalence, impact on daily living and desire for treatment: a population-based study. Scand J Urol Nephrol. 2004;38(2):125-30. [pmid: 15204395].
38 McGrother CW, Donaldson MM, Shaw C, et al. Storage symptoms of the bladder: prevalence, incidence and need for services in the UK. BJU Int. Apr. 2004;93(6):763-9. [pmid: 15049987].
39 Mardon RE, Halim S, Pawlson LG, et al. Management of urinary incontinence in Medicare managed care beneficiaries: results from the 2004 Medicare Health Outcomes Survey. Arch Intern Med. May 22. 2006;166(10):1128-33. [pmid: 16717176].
40 Rekers H, Drogendijk AC, Valkenburg HA, et al. The menopause, urinary incontinence and other symptoms of the genito-urinary tract. Maturitas. Oct. 1992;15(2):101-11. [pmid: 1470043].
41 Rekers H, Drogendijk AC, Valkenburg H, et al. Urinary incontinence in women from 35 to 79 years of age: prevalence and consequences. Eur J Obstet Gynecol Reprod Biol. Feb 28. 1992;43(3):229-34. [pmid: 1563575].
42 Kok AL, Voorhorst FJ, Burger CW, et al. Urinary and faecal incontinence in community-residing elderly women. Age Ageing. May. 1992;21(3):211-5. [pmid: 1615785].
43 O'Brien J, Austin M, Sethi P, et al. Urinary incontinence: prevalence, need for treatment, and effectiveness of intervention by nurse. BMJ. Nov 23. 1991;303(6813):1308-12. [pmid: 1747675]. [pmcid: 1671402].
44 Burgio KL, Burgio LD, McCormick KA, et al. Assessing toileting skills and habits in an adult day care center. J Gerontol Nurs. Dec. 1991;17(12):32-5. [pmid: 1761819].
45 Burgio KL, Matthews KA, Engel BT. Prevalence, incidence and correlates of urinary incontinence in healthy, middle-aged women. J Urol. Nov. 1991;146(5):1255-9. [pmid: 1942274].
46 Lagro-Janssen TL, Smits AJ, Van Weel C. Women with urinary incontinence: self-perceived worries and general practitioners' knowledge of problem. Br J Gen Pract. Aug. 1990;40(337):331-4. [pmid: 2121179]. [pmcid: 1371311].
47 Herzog AR, Diokno AC, Brown MB, et al. Two-year incidence, remission, and change patterns of urinary incontinence in noninstitutionalized older adults. J Gerontol. Mar. 1990;45(2):M67-74. [pmid: 2313045].
48 Molander U, Milsom I, Ekelund P, et al. An epidemiological study of urinary incontinence and related urogenital symptoms in elderly women. Maturitas. Apr. 1990;12(1):51-60. [pmid: 2333037].
49 Seim A, Sandvik H, Hermstad R, et al. Female urinary incontinence—consultation behaviour and patient experiences: an epidemiological survey in a Norwegian community. Fam Pract. Mar. 1995;12(1):18-21. [pmid: 7665034].
50 Wetle T, Scherr P, Branch LG, et al. Difficulty with holding urine among older persons in a geographically defined community: prevalence and correlates. J Am Geriatr Soc. Apr. 1995;43(4):349-55. [pmid: 7706622].
51 Mommsen S, Foldspang A. Body mass index and adult female urinary incontinence. World J Urol. 1994;12(6):319-22. [pmid: 7881469].
52 Brocklehurst JC. Urinary incontinence in the community—analysis of a MORI poll. BMJ. Mar 27. 1993;306(6881):832-4. [pmid: 8490377]. [pmcid: 1677310].
53 Milsom I, Ekelund P, Molander U, et al. The influence of age, parity, oral contraception, hysterectomy and menopause on the prevalence of urinary incontinence in women. J Urol. Jun. 1993;149(6):1459-62. [pmid: 8501788].
54 Lagace EA, Hansen W, Hickner JM. Prevalence and severity of urinary incontinence in ambulatory adults: an UPRNet study. J Fam Pract. Jun. 1993;36(6):610-4. [pmid: 8505603].
55 Brown JS, Seeley DG, Fong J, et al. Urinary incontinence in older women: who is at risk? Study of Osteoporotic Fractures Research Group. Obstet Gynecol. May. 1996;87(5 Pt 1):715-21. [pmid: 8677073].
56 Nygaard IE, Lemke JH. Urinary incontinence in rural older women: prevalence, incidence and remission. J Am Geriatr Soc. Sep. 1996;44(9):1049-54. [pmid: 8790229].
57 Samuelsson E, Victor A, Tibblin G. A population study of urinary incontinence and nocturia among women aged 20–59 years. Prevalence, well-being and wish for treatment. Acta Obstet Gynecol Scand. Jan. 1997;76(1):74-80. [pmid: 9033249].
58 Nakanishi N, Tatara K, Naramura H, et al. Urinary and fecal incontinence in a community-residing older population in Japan. J Am Geriatr Soc. Feb. 1997;45(2):215-9. [pmid: 9033523].
59 Thom DH, van den Eeden SK, Brown JS. Evaluation of parturition and other reproductive variables as risk factors for urinary incontinence in later life. Obstet Gynecol. Dec. 1997;90(6):983-9. [pmid: 9397116].
60 Brieger GM, Mongelli M, Hin LY, et al. The epidemiology of urinary dysfunction in Chinese women. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):191-5. [pmid: 9449294].
61 Bogren MA, Hvarfwen E, Fridlund B. Urinary incontinence among a 65-year old Swedish population: medical history and psychosocial consequences. Vard Nord Utveckl Forsk. Winter. 1997;17(4):14-7.
62 Holtedahl K, Hunskaar S. Prevalence, 1-year incidence and factors associated with urinary incontinence: a population based study of women 50–74 years of age in primary care. Maturitas. Jan 12. 1998;28(3):205-11. [pmid: 9571595].
63 Koyama W, Koyanagi A, Mihara S, et al. Prevalence and conditions of urinary incontinence among the elderly. Methods Inf Med. Jun. 1998;37(2):151-5. [pmid: 9656656].
64 Foldspang A, Mommsen S, Djurhuus JC. Prevalent urinary incontinence as a correlate of pregnancy, vaginal childbirth, and obstetric techniques. Am J Public Health. Feb. 1999;89(2):209-12. [pmid: 9949751]. [pmcid: 1508519].
65 Dolan LM, Casson K, McDonald P, et al. Urinary incontinence in Northern Ireland: a prevalence study. BJU Int. May. 1999;83(7):760-6. [pmid: 10368192].
66 Brown JS, Grady D, Ouslander JG, et al. Prevalence of urinary incontinence and associated risk factors in postmenopausal women. Heart & Estrogen/Progestin Replacement Study (HERS) Research Group. Obstet Gynecol. Jul. 1999;94(1):66-70. [pmid: 10389720].
67 Fultz NH, Herzog AR, Raghunathan TE, et al. Prevalence and severity of urinary incontinence in older African American and Caucasian women. J Gerontol A Biol Sci Med Sci. Jun. 1999;54(6):M299-303. [pmid: 10411017].
68 Chiarelli P, Brown W, McElduff P. Leaking urine: prevalence and associated factors in Australian women. Neurourol Urodyn. 1999;18(6):567-77. [pmid: 10529705].
69 Hagglund D, Olsson H, Leppert J. Urinary incontinence: an unexpected large problem among young females. Results from a population-based study. Fam Pract. Oct. 1999;16(5):506-9. [pmid: 10533948].
70 Kuh D, Cardozo L, Hardy R. Urinary incontinence in middle aged women: childhood enuresis and other lifetime risk factors in a British prospective cohort. J Epidemiol Community Health. Aug. 1999;53(8):453-8. [pmid: 10562862]. [pmcid: 1756946].
71 Stenberg A, Heimer G, Holmberg L, et al. Prevalence of postmenopausal symptoms in two age groups of elderly women in relation to oestrogen replacement therapy. Maturitas. Dec 15. 1999;33(3):229-37. [pmid: 10656501].
72 Bortolotti A, Bernardini B, Colli E, et al. Prevalence and risk factors for urinary incontinence in Italy. Eur Urol. Jan. 2000;37(1):30-5. [pmid: 10671782].
73 Moller LA, Lose G, Jorgensen T. The prevalence and bothersomeness of lower urinary tract symptoms in women 40–60 years of age. Acta Obstet Gynecol Scand. Apr. 2000;79(4):298-305. [pmid: 10746846].
74 Ueda T, Tamaki M, Kageyama S, et al. Urinary incontinence among community-dwelling people aged 40 years or older in Japan: prevalence, risk factors, knowledge and self-perception. Int J Urol. Mar. 2000;7(3):95-103. [pmid: 10750888].
75 Temml C, Haidinger G, Schmidbauer J, et al. Urinary incontinence in both sexes: prevalence rates and impact on quality of life and sexual life. Neurourol Urodyn. 2000;19(3):259-71. [pmid: 10797583].
76 Gavira Iglesias FJ, Caridad y Ocerin JM, Perez del Molino Martin J, et al. Prevalence and psychosocial impact of urinary incontinence in older people of a Spanish rural population. J Gerontol A Biol Sci Med Sci. Apr. 2000;55(4):M207-14. [pmid: 10811150].
77 Swithinbank LV, Donovan JL, du Heaume JC, et al. Urinary symptoms and incontinence in women: relationships between occurrence, age, and perceived impact. Br J Gen Pract. Nov. 1999;49(448):897-900. [pmid: 10818656]. [pmcid: 1313561].
78 Alling Moller L, Lose G, Jorgensen T. Risk factors for lower urinary tract symptoms in women 40 to 60 years of age. Obstet Gynecol. Sep. 2000;96(3):446-51. [pmid: 10960640].
79 Tseng IJ, Chen YT, Chen MT, et al. Prevalence of urinary incontinence and intention to seek treatment in the elderly. J Formos Med Assoc. Oct. 2000;99(10):753-8. [pmid: 11061069].
80 Hannestad YS, Rortveit G, Sandvik H, et al. A community-based epidemiological survey of female urinary incontinence: the Norwegian EPINCONT study. Epidemiology of Incontinence in the County of Nord-Trondelag. J Clin Epidemiol. Nov. 2000;53(11):1150-7. [pmid: 11106889].
81 Maggi S, Minicuci N, Langlois J, et al. Prevalence rate of urinary incontinence in community-dwelling elderly individuals: the Veneto study. J Gerontol A Biol Sci Med Sci. Jan. 2001;56(1):M14-8. [pmid: 11193226].
82 Stoddart H, Donovan J, Whitley E, et al. Urinary incontinence in older people in the community: a neglected problem?. Br J Gen Pract. Jul. 2001;51(468):548-52. [pmid: 11462314]. [pmcid: 1314046].
83 Schmidbauer J, Temml C, Schatzl G, et al. Risk factors for urinary incontinence in both sexes. Analysis of a health screening project. Eur Urol. May. 2001;39(5):565-70. [pmid: 11464038].
84 Muscatello DJ, Rissel C, Szonyi G. Urinary symptoms and incontinence in an urban community: prevalence and associated factors in older men and women. Intern Med J. Apr. 2001;31(3):151-60. [pmid: 11478344].
85 Peyrat L, Haillot O, Bruyere F, et al. Prevalence and risk factors of urinary incontinence in young and middle-aged women. BJU Int. Jan. 2002;89(1):61-6. [pmid: 11849162].
86 Finkelstein MM. Medical conditions, medications, and urinary incontinence. Analysis of a population-based survey. Can Fam Physician. Jan. 2002;48:96-101. [pmid: 11852617]. [pmcid: 2213925].
87 van der Vaart CH, van der Bom JG, de Leeuw JR, et al. The contribution of hysterectomy to the occurrence of urge and stress urinary incontinence symptoms. Bjog. Feb. 2002;109(2):149-54. [pmid: 11911100].
88 Bogner HR, Gallo JJ, Sammel MD, et al. Urinary incontinence and psychological distress in community-dwelling older adults. J Am Geriatr Soc. Mar. 2002;50(3):489-95. [pmid: 11943045].
89 Sze EH, Jones WP, Ferguson JL, et al. Prevalence of urinary incontinence symptoms among black, white, and Hispanic women. Obstet Gynecol. Apr. 2002;99(4):572-5. [pmid: 12039113].
90 Buchsbaum GM, Chin M, Glantz C, et al. Prevalence of urinary incontinence and associated risk factors in a cohort of nuns. Obstet Gynecol. Aug. 2002;100(2):226-9. [pmid: 12151141].
91 van der Vaart CH, de Leeuw JR, Roovers JP, et al. The effect of urinary incontinence and overactive bladder symptoms on quality of life in young women. BJU Int. Oct. 2002;90(6):544-9. [pmid: 12230614].
92 Van Oyen H, Van Oyen P. Urinary incontinence in Belgium; prevalence, correlates and psychosocial consequences. Acta Clin Belg. Jul–Aug. 2002;57(4):207-18. [pmid: 12462797].
93 Sampselle CM, Harlow SD, Skurnick J, et al. Urinary incontinence predictors and life impact in ethnically diverse perimenopausal women. Obstet Gynecol. Dec. 2002;100(6):1230-8. [pmid: 12468167].
94 Landi F, Cesari M, Russo A, et al. Benzodiazepines and the risk of urinary incontinence in frail older persons living in the community. Clin Pharmacol Ther. Dec. 2002;72(6):729-34. [pmid: 12496754].
95 Chen GD, Lin TL, Hu SW, et al. Prevalence and correlation of urinary incontinence and overactive bladder in Taiwanese women. Neurourol Urodyn. 2003;22(2):109-17. [pmid: 12579627].
96 Hvidman L, Foldspang A, Mommsen S, et al. Menstrual cycle, female hormone use and urinary incontinence in premenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):56-61. discussion. [pmid: 12601518].
97 Landi F, Cesari M, Russo A, et al. Potentially reversible risk factors and urinary incontinence in frail older people living in community. Age Ageing. Mar. 2003;32(2):194-9. [pmid: 12615564].
98 Rortveit G, Daltveit AK, Hannestad YS, et al. Urinary incontinence after vaginal delivery or cesarean section. N Engl J Med. Mar 6. 2003;348(10):900-7. [pmid: 12621134].
99 Eva UF, Gun W, Preben K. Prevalence of urinary and fecal incontinence and symptoms of genital prolapse in women. Acta Obstet Gynecol Scand. Mar. 2003;82(3):280-6. [pmid: 12694126].
100 Miller YD, Brown WJ, Smith N, et al. Managing urinary incontinence across the lifespan. Int J Behav Med. 2003;10(2):143-61. [pmid: 12763707].
101 Chen YC, Chen GD, Hu SW, et al. Is the occurrence of storage and voiding dysfunction affected by menopausal transition or associated with the normal aging process?. Menopaus. May–Jun. 2003;10(3):203-8.
102 Stewart WF, Van Rooyen JB, Cundiff GW, et al. Prevalence and burden of overactive bladder in the United States. World J Urol. May. 2003;20(6):327-36. [pmid: 12811491].
103 Dallosso HM, McGrother CW, Matthews RJ, et al. The association of diet and other lifestyle factors with overactive bladder and stress incontinence: a longitudinal study in women. BJU Int. Jul. 2003;92(1):69-77. [pmid: 12823386].
104 Miller YD, Brown WJ, Russell A, et al. Urinary incontinence across the lifespan. Neurourol Urodyn. 2003;22(6):550-7. [pmid: 12951662].
105 Grodstein F, Fretts R, Lifford K, et al. Association of age, race, and obstetric history with urinary symptoms among women in the Nurses' Health Study. Am J Obstet Gynecol. Aug. 2003;189(2):428-34. [pmid: 14520212].
106 Nuotio M, Jylha M, Luukkaala T, et al. Urinary incontinence in a Finnish population aged 70 and over. Prevalence of types, associated factors and self-reported treatments. Scand J Prim Health Care. Sep. 2003;21(3):182-7. [pmid: 14531512].
107 Araki I, Zakoji H, Komuro M, et al. Lower urinary tract symptoms in men and women without underlying disease causing micturition disorder: a cross-sectional study assessing the natural history of bladder function. J Urol. Nov. 2003;170(5):1901-4. [pmid: 14532803].
108 Parazzini F, Chiaffarino F, Lavezzari M, et al. Risk factors for stress, urge or mixed urinary incontinence in Italy. Bjog. Oct. 2003;110(10):927-33. [pmid: 14550363].
109 Mawajdeh SM, Al-Qutob R, Schmidt A. Measuring reproductive morbidity: a community-based approach, Jordan. Health Care Women Int. Aug. 2003;24(7):635-49. [pmid: 14627210].
110 Espino DV, Palmer RF, Miles TP, et al. Prevalence and severity of urinary incontinence in elderly Mexican-American women. J Am Geriatr Soc. Nov. 2003;51(11):1580-6. [pmid: 14687387].
111 Teunissen TA, van den Bosch WJ, van den Hoogen HJ, et al. Prevalence of urinary, fecal and double incontinence in the elderly living at home. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):10-3. discussion 3. [pmid: 14752592].
112 Hunskaar S, Lose G, Sykes D, et al. The prevalence of urinary incontinence in women in four European countries. BJU Int. Feb. 2004;93(3):324-30. [pmid: 14764130].
113 Holroyd-Leduc JM, Mehta KM, Covinsky KE. Urinary incontinence and its association with death, nursing home admission, and functional decline. J Am Geriatr Soc. May. 2004;52(5):712-8. [pmid: 15086650].
114 Stenzelius K, Mattiasson A, Hallberg IR, et al. Symptoms of urinary and faecal incontinence among men and women 75+ in relations to health complaints and quality of life. Neurourol Urodyn. 2004;23(3):211-22. [pmid: 15098216].
115 Lagergren M, Fratiglioni L, Hallberg IR, et al. A longitudinal study integrating population, care and social services data. The Swedish National study on Aging and Care (SNAC). Aging Clin Exp Res. Apr. 2004;16(2):158-68. [pmid: 15195992].
116 Ozerdogan N, Beji NK, Yalcin O. Urinary incontinence: its prevalence, risk factors and effects on the quality of life of women living in a region of Turkey. Gynecol Obstet Invest. 2004;58(3):145-50. [pmid: 15237249].
117 Corcos J, Schick E. Prevalence of overactive bladder and incontinence in Canada. Can J Urol. Jun. 2004;11(3):2278-84. [pmid: 15287994].
118 Jackson RA, Vittinghoff E, Kanaya AM, et al. Urinary incontinence in elderly women: findings from the Health, Aging, and Body Composition Study. Obstet Gynecol. Aug. 2004;104(2):301-7. [pmid: 15292003].
119 Schytt E, Lindmark G, Waldenstrom U. Symptoms of stress incontinence 1 year after childbirth: prevalence and predictors in a national Swedish sample. Acta Obstet Gynecol Scand. Oct. 2004;83(10):928-36. [pmid: 15453888].
120 Bogner HR. Urinary incontinence and psychological distress in community-dwelling older African Americans and whites. J Am Geriatr Soc. Nov. 2004;52(11):1870-4. [pmid: 15507064].
121 Oskay UY, Beji NK, Yalcin O. A study on urogenital complaints of postmenopausal women aged 50 and over. Acta Obstet Gynecol Scand. Jan. 2005;84(1):72-8. [pmid: 15603571].
122 Vandoninck V, Bemelmans BL, Mazzetta C, et al. The prevalence of urinary incontinence in community-dwelling married women: a matter of definition. BJU Int. Dec. 2004;94(9):1291-5. [pmid: 15610108].
123 Jackson SL, Boyko EJ, Scholes D, et al. Predictors of urinary tract infection after menopause: a prospective study. Am J Med. Dec 15. 2004;117(12):903-11. [pmid: 15629728].
124 Melville JL, Katon W, Delaney K, et al. Urinary incontinence in US women: a population-based study. Arch Intern Med. Mar 14. 2005;165(5):537-42. [pmid: 15767530].
125 Bradley CS, Kennedy CM, Nygaard IE. Pelvic floor symptoms and lifestyle factors in older women. J Womens Health (Larchmt). Mar. 2005;14(2):128-36. [pmid: 15775730].
126 Ruff CC. Risk factors for urinary incontinence in African-American women. Urol Nurs. Feb. 2005;25(1):33-9. [pmid: 15779690].
127 Kocak I, Okyay P, Dundar M, et al. Female urinary incontinence in the west of Turkey: prevalence, risk factors and impact on quality of life. Eur Urol. Oct. 2005;48(4):634-41. [pmid: 15963633].
128 Jackson SL, Scholes D, Boyko EJ, et al. Urinary incontinence and diabetes in postmenopausal women. Diabetes Care. Jul. 2005;28(7):1730-8. [pmid: 15983327].
129 Tegerstedt G, Maehle-Schmidt M, Nyren O, et al. Prevalence of symptomatic pelvic organ prolapse in a Swedish population. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):497-503. [pmid: 15986100].
130 Nygaard I, Girts T, Fultz NH, et al. Is urinary incontinence a barrier to exercise in women?. Obstet Gynecol. Aug. 2005;106(2):307-14. [pmid: 16055580].
131 Teleman P, Lidfeldt J, Nerbrand C, et al. Lower urinary tract symptoms in middle-aged women—prevalence and attitude towards mild urinary incontinence: a community-based population study. Acta Obstet Gynecol Scand. Nov. 2005;84(11):1108-12. [pmid: 16232181].
132 McGrother CW, Donaldson MM, Hayward T, et al. Urinary storage symptoms and comorbidities: a prospective population cohort study in middle-aged and older women. Age Ageing. Jan. 2006;35(1):16-24. [pmid: 16234314].
133 Rohr G, Stovring H, Christensen K, et al. Characteristics of middle-aged and elderly women with urinary incontinence. Scand J Prim Health Care. Dec. 2005;23(4):203-8. [pmid: 16272067].
134 Lifford KL, Curhan GC, Hu FB, et al. Type 2 diabetes mellitus and risk of developing urinary incontinence. J Am Geriatr Soc. Nov. 2005;53(11):1851-7. [pmid: 16274364].
135 Fritel X, Ringa V, Varnoux N, et al. Mode of delivery and severe stress incontinence. a cross-sectional study among 2,625 perimenopausal women. Bjog. Dec. 2005;112(12):1646-51. [pmid: 16305569].
136 Goldberg RP, Abramov Y, Botros S, et al. Delivery mode is a major environmental determinant of stress urinary incontinence: results of the Evanston-Northwestern Twin Sisters Study. Am J Obstet Gynecol. Dec. 2005;193(6):2149-53. [pmid: 16325632].
137 Thom DH, van den Eeden SK, Ragins AI, et al. Differences in prevalence of urinary incontinence by race/ethnicity. J Urol. Jan. 2006;175(1):259-64. [pmid: 16406923]. [pmcid: 1557354].
138 Danforth KN, Townsend MK, Lifford K, et al. Risk factors for urinary incontinence among middle-aged women. Am J Obstet Gynecol. Feb. 2006;194(2):339-45. [pmid: 16458626]. [pmcid: 1363686].
139 Wehrberger C, Temml C, Ponholzer A, et al. Incidence and remission of female urinary incontinence over 6.5 years: analysis of a health screening project. Eur Urol. Aug. 2006;50(2):327-32. [pmid: 16517050].
140 Brown JS, Vittinghoff E, Lin F, et al. Prevalence and risk factors for urinary incontinence in women with type 2 diabetes and impaired fasting glucose: findings from the National Health and Nutrition Examination Survey (NHANES) 2001-2002. Diabetes Care. Jun. 2006;29(6):1307-12. [pmid: 16732013]. [pmcid: 1557358].
141 Lukacz ES, Lawrence JM, Contreras R, et al. Parity, mode of delivery, and pelvic floor disorders. Obstet Gynecol. Jun. 2006;107(6):1253-60. [pmid: 16738149].
142 Tannenbaum C, Corcos J, Assalian P. The relationship between sexual activity and urinary incontinence in older women. J Am Geriatr Soc. Aug. 2006;54(8):1220-4. [pmid: 16913988].
143 Swanson JG, Kaczorowski J, Skelly J, et al. Urinary incontinence: common problem among women over 45. Can Fam Physician. Jan. 2005;51:84-5. [pmid: 16926957]. [pmcid: 1479575].
144 Jackson SL, Scholes D, Boyko EJ, et al. Predictors of urinary incontinence in a prospective cohort of postmenopausal women. Obstet Gynecol. Oct. 2006;108(4):855-62. [pmid: 17012446].
145 Irwin DE, Milsom I, Hunskaar S, et al. Population-based survey of urinary incontinence, overactive bladder, and other lower urinary tract symptoms in five countries: results of the EPIC study. Eur Urol. Dec. 2006;50(6):1306-14. discussion 14–5. [pmid: 17049716].
146 Harris SS, Link CL, Tennstedt SL, et al. Care seeking and treatment for urinary incontinence in a diverse population. J Urol. Feb. 2007;177(2):680-4. [pmid: 17222656].
147 Huang AJ, Brown JS, Thom DH, et al. Urinary incontinence in older community-dwelling women: the role of cognitive and physical function decline. Obstet Gynecol. Apr. 2007;109(4):909-16. [pmid: 17400853].
148 Kinchen KS, Lee J, Fireman B, et al. The prevalence, burden, and treatment of urinary incontinence among women in a managed care plan. J Womens Health (Larchmt). Apr. 2007;16(3):415-22. [pmid: 17439386].
149 Waetjen LE, Liao S, Johnson WO, et al. Factors associated with prevalent and incident urinary incontinence in a cohort of midlife women: a longitudinal analysis of data: study of women's health across the nation. Am J Epidemiol. Feb 1. 2007;165(3):309-18. [pmid: 17132698].
150 Moller LA, Lose G, Jorgensen T. Incidence and remission rates of lower urinary tract symptoms at one year in women aged 40–60: longitudinal study. BMJ. May 27. 2000;320(7247):1429-32. [pmid: 10827042]. [pmcid: 27383].
151 Samuelsson EC, Victor FT, Svardsudd KF. Five-year incidence and remission rates of female urinary incontinence in a Swedish population less than 65 years old. Am J Obstet Gynecol. Sep. 2000;183(3):568-74. [pmid: 10992175].
152 Sherburn M, Guthrie JR, Dudley EC, et al. Is incontinence associated with menopause?. Obstet Gynecol. Oct. 2001;98(4):628-33. [pmid: 11576579].
153 Grodstein F, Lifford K, Resnick NM, et al. Postmenopausal hormone therapy and risk of developing urinary incontinence. Obstet Gynecol. Feb. 2004;103(2):254-60. [pmid: 14754692].
154 Dallosso H, Matthews R, McGrother C, et al. Diet as a risk factor for the development of stress urinary incontinence: a longitudinal study in women. Eur J Clin Nutr. Jun. 2004;58(6):920-6. [pmid: 15164113].
155 Hagglund D, Walker-Engstrom ML, Larsson G, et al. Changes in urinary incontinence and quality of life after four years. A population-based study of women aged 22–50 years. Scand J Prim Health Care. Jun. 2004;22(2):112-7. [pmid: 15255492].
156 Danforth KN, Shah AD, Townsend MK, et al. Physical activity and urinary incontinence among healthy, older women. Obstet Gynecol. Mar. 2007;109(3):721-7. [pmid: 17329526].
157 Townsend MK, Danforth KN, Rosner B, et al. Body Mass Index, Weight Gain, and Incident Urinary Incontinence in Middle-Aged Women. Obstet Gynecol. Aug. 2007;110(2):346-53. [pmid: 17666610].
158 Bliss DZ, Fischer LR, Savik K, et al. Severity of fecal incontinence in community-living elderly in a health maintenance organization. Res Nurs Health. Jun. 2004;27(3):162-73. [pmid: 15141369].
159 Johanson JF, Lafferty J. Epidemiology of fecal incontinence: the silent affliction. Am J Gastroenterol. Jan. 1996;91(1):33-6. [pmid: 8561140].
160 Talley NJ, O'Keefe EA, Zinsmeister AR, et al. Prevalence of gastrointestinal symptoms in the elderly: a population-based study. Gastroenterology. Mar. 1992;102(3):895-901. [pmid: 1537525].
161 Bharucha AE, Zinsmeister AR, Locke GR, et al. Prevalence and burden of fecal incontinence: a population-based study in women. Gastroenterology. Jul. 2005;129(1):42-9. [pmid: 16012933].
162 Ballester A, Minguez M, Herreros B, et al. Prevalence of silent fecal and urinary incontinence in women from the town of Teruel. Rev Esp Enferm Dig. Feb. 2005;97(2):78-86. [pmid: 15801883].
163 Melville JL, Fan MY, Newton K, et al. Fecal incontinence in US women: a population-based study. Am J Obstet Gynecol. Dec. 2005;193(6):2071-6. [pmid: 16325618].
164 Brandeis GH, Baumann MM, Hossain M, et al. The prevalence of potentially remediable urinary incontinence in frail older people: a study using the Minimum Data Set. J Am Geriatr Soc. Feb. 1997;45(2):179-84. [pmid: 9033516].
165 Nelson R, Furner S, Jesudason V. Urinary incontinence in Wisconsin skilled nursing facilities: prevalence and associations in common with fecal incontinence. J Aging Health. Nov. 2001;13(4):539-47. [pmid: 11813740].
166 Ouslander JG, Palmer MH, Rovner BW, et al. Urinary incontinence in nursing homes: incidence, remission and associated factors. J Am Geriatr Soc. Oct. 1993;41(10):1083-9. [pmid: 8409154].
167 Talcott JA, Rieker P, Clark JA, et al. Patient-reported symptoms after primary therapy for early prostate cancer: results of a prospective cohort study. J Clin Oncol. Jan. 1998;16(1):275-83. [pmid: 9440753].
168 Joly F, Brune D, Couette JE, et al. Health-related quality of life and sequelae in patients treated with brachytherapy and external beam irradiation for localized prostate cancer. Ann Oncol. Jul. 1998;9(7):751-7. [pmid: 9739442].
169 Augustin H, Pummer K, Daghofer F, et al. Patient self-reporting questionnaire on urological morbidity and bother after radical retropubic prostatectomy. Eur Urol. Aug. 2002;42(2):112-17. [pmid: 12160580].
170 Liu M, Pickles T, Berthelet E, et al. Urinary incontinence in prostate cancer patients treated with external beam radiotherapy. Radiother Oncol. Feb. 2005;74(2):197-201. [pmid: 15818868].
171 Jacobsen NE, Moore KN, Estey E, et al. Open versus laparoscopic radical prostatectomy: a prospective comparison of postoperative urinary incontinence rates. J Urol. Feb. 2007;177(2):615-9. [pmid: 17222646].
172 Johnson TK, Gilliland FD, Hoffman RM, et al. Racial/Ethnic differences in functional outcomes in the 5 years after diagnosis of localized prostate cancer. J Clin Oncol. Oct 15. 2004;22(20):4193-201. [pmid: 15483030].
173 Lee WR, Schultheiss TE, Hanlon AL, et al. Urinary incontinence following external-beam radiotherapy for clinically localized prostate cancer. Urology. Jul. 1996;48(1):95-9. [pmid: 8693660].
174 Sandhu AS, Zelefsky MJ, Lee HJ, et al. Long-term urinary toxicity after 3-dimensional conformal radiotherapy for prostate cancer in patients with prior history of transurethral resection. Int J Radiat Oncol Biol Phys. Oct 1. 2000;48(3):643-7. [pmid: 11020559].
175 Hu JC, Gold KF, Pashos CL, et al. Temporal trends in radical prostatectomy complications from 1991 to 1998. J Urol. Apr. 2003;169(4):1443-8. [pmid: 12629380].
176 Koskimaki J, Hakama M, Huhtala H, et al. Association of non-urological diseases with lower urinary tract symptoms. Scand J Urol Nephrol. Oct. 2001;35(5):377-81. [pmid: 11771864].
177 Jorgensen L, Engstad T, Jacobsen BK. Self-reported urinary incontinence in noninstitutionalized long-term stroke survivors: A population-based study. Arch Phys Med Rehabil. Mar. 2005;86(3):416-20. [pmid: 15759221].
178 Tellez-Zenteno JF, Matijevic S, Wiebe S. Somatic comorbidity of epilepsy in the general population in Canada. Epilepsia. Dec. 2005;46(12):1955-62. [pmid: 16393162].
179 Roberts RO, Jacobsen SJ, Jacobson DJ, et al. Natural history of prostatism: high American Urological Association Symptom scores among community-dwelling men and women with urinary incontinence. Urology. Feb. 1998;51(2):213-9. [pmid: 9495700].
180 Adolfsson J, Helgason AR, Dickman P, et al. Urinary and bowel symptoms in men with and without prostate cancer: results from an observational study in the Stockholm area. Eur Urol. 1998;33(1):11-6.
181 Smoger SH, Felice TL, Kloecker GH. Urinary incontinence among male veterans receiving care in primary care clinics. Ann Intern Med. Apr 4. 2000;132(7):547-51. [pmid: 10744591].
182 Hisasue S, Takahashi A, Kato R, et al. Early and late complications of radical retropubic prostatectomy: experience in a single institution. Jpn J Clin Oncol. May. 2004;34(5):274-9. [pmid: 15231863].
183 Burkhard FC, Kessler TM, Fleischmann A, et al. Nerve sparing open radical retropubic prostatectomy—does it have an impact on urinary continence?. J Urol. Jul. 2006;176(1):189-95. [pmid: 16753399].
184 Roe B, Doll H, Wilson K. Help seeking behaviour and health and social services utilisation by people suffering from urinary incontinence. Int J Nurs Stud. Jun. 1999;36(3):245-53. [pmid: 10404294].
185 Uustal Fornell E, Wingren G, Kjolhede P. Factors associated with pelvic floor dysfunction with emphasis on urinary and fecal incontinence and genital prolapse: an epidemiological study. Acta Obstet Gynecol Scand. Apr. 2004;83(4):383-9. [pmid: 15005787].
186 Ostbye T, Seim A, Krause KM, et al. A 10-year follow-up of urinary and fecal incontinence among the oldest old in the community: the Canadian Study of Health and Aging. Can J Aging. Winter. 2004;23(4):319-31. [pmid: 15838815].
187 Huang AJ, Thom DH, Kanaya AM, et al. Urinary incontinence and pelvic floor dysfunction in Asian-American women. Am J Obstet Gynecol. Nov. 2006;195(5):1331-7. [pmid: 16643821]. [pmcid: 1630451].
188 Fitzgerald ST, Palmer MH, Kirkland VL, et al. The impact of urinary incontinence in working women: a study in a production facility. Women Health. 2002;35(1):1-16. [pmid: 11942466].
189 Nygaard I, Turvey C, Burns TL, et al. Urinary incontinence and depression in middle-aged United States women. Obstet Gynecol. Jan. 2003;101(1):149-56. [pmid: 12517660].
190 Teleman PM, Lidfeldt J, Nerbrand C, et al. Overactive bladder: prevalence, risk factors and relation to stress incontinence in middle-aged women. Bjog. Jun. 2004;111(6):600-4. [pmid: 15198789].
191 Moghaddas F, Lidfeldt J, Nerbrand C, et al. Prevalence of urinary incontinence in relation to self-reported depression, intake of serotonergic antidepressants, and hormone therapy in middle-aged women: a report from the Women's Health in the Lund Area study. Menopause. May–Jun. 2005;12(3):318-24. [pmid: 15879921].
192 Hannestad YS, Rortveit G, Daltveit AK, et al. Are smoking and other lifestyle factors associated with female urinary incontinence? The Norwegian EPINCONT Study. Bjog. Mar. 2003;110(3):247-54. [pmid: 12628262].
193 Wilson PD, Herbison RM, Herbison GP. Obstetric practice and the prevalence of urinary incontinence three months after delivery. Br J Obstet Gynaecol. Feb. 1996;103(2):154-61. [pmid: 8616133].
194 Burgio KL, Locher JL, Zyczynski H, et al. Urinary incontinence during pregnancy in a racially mixed sample: characteristics and predisposing factors. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):69-73. [pmid: 8798089].
195 Rortveit G, Hannestad YS, Daltveit AK, et al. Age- and type-dependent effects of parity on urinary incontinence: the Norwegian EPINCONT study. Obstet Gynecol. Dec. 2001;98(6):1004-10. [pmid: 11755545].
196 Altman D, Ekstrom A, Gustafsson C, et al. Risk of urinary incontinence after childbirth: a 10-year prospective cohort study. Obstet Gynecol. Oct. 2006;108(4):873-8. [pmid: 17012448].
197 Glazener CM, Herbison GP, MacArthur C, et al. New postnatal urinary incontinence: obstetric and other risk factors in primiparae. Bjog. Feb. 2006;113(2):208-17. [pmid: 16412000].
198 Burgio KL, Zyczynski H, Locher JL, et al. Urinary incontinence in the 12-month postpartum period. Obstet Gynecol. Dec. 2003;102(6):1291-8. [pmid: 14662217].
199 Farrell SA, Allen VM, Baskett TF. Parturition and urinary incontinence in primiparas. Obstet Gynecol. Mar. 2001;97(3):350-6. [pmid: 11239635].
200 Thompson JF, Roberts CL, Currie M, et al. Prevalence and persistence of health problems after childbirth: associations with parity and method of birth. Birth. Jun. 2002;29(2):83-94. [pmid: 12051189].
201 Hvidman L, Foldspang A, Mommsen S, et al. Postpartum urinary incontinence. Acta Obstet Gynecol Scand. Jun. 2003;82(6):556-63. [pmid: 12780427].
202 Casey BM, Schaffer JI, Bloom SL, et al. Obstetric antecedents for postpartum pelvic floor dysfunction. Am J Obstet Gynecol. May. 2005;192(5):1655-62. [pmid: 15902173].
203 Burgio KL, Borello-France D, Richter HE, et al. Risk Factors for Fecal and Urinary Incontinence After Childbirth: The Childbirth and Pelvic Symptoms Study. Am J Gastroenterol 2007 Jun 15.
204 Hojberg KE, Salvig JD, Winslow NA, et al. Urinary incontinence: prevalence and risk factors at 16 weeks of gestation. Br J Obstet Gynaecol. Aug. 1999;106(8):842-50. [pmid: 10453836].
205 Chaliha C, Kalia V, Stanton SL, et al. Antenatal prediction of postpartum urinary and fecal incontinence. Obstet Gynecol. Nov. 1999;94(5 Pt 1):689-94. [pmid: 10546711].
206 Rortveit G, Daltveit AK, Hannestad YS, et al. Vaginal delivery parameters and urinary incontinence: the Norwegian EPINCONT study. Am J Obstet Gynecol. Nov. 2003;189(5):1268-74. [pmid: 14634552].
207 Haraguchi K, Takahashi H, Tanaka H, et al. Synthesis and antiviral activities of 1′-carbon-substituted 4′-thiothymidines. Bioorg Med Chem. Oct 15. 2004;12(20):5309-16. [pmid: 15388158].
208 Richter HE, Burgio KL, Clements RH, et al. Urinary and anal incontinence in morbidly obese women considering weight loss surgery. Obstet Gynecol. Dec. 2005;106(6):1272-7. [pmid: 16319252].
209 Pollack J, Nordenstam J, Brismar S, et al. Anal incontinence after vaginal delivery: a five-year prospective cohort study. Obstet Gynecol. Dec. 2004;104(6):1397-402. [pmid: 15572505].
210 Ng SC, Chen YC, Lin LY, et al. Anorectal dysfunction in women with urinary incontinence or lower urinary tract symptoms. Int J Gynaecol Obstet. May. 2002;77(2):139-45. [pmid: 12031564].
211 Meschia M, Buonaguidi A, Pifarotti P, et al. Prevalence of anal incontinence in women with symptoms of urinary incontinence and genital prolapse. Obstet Gynecol. Oct. 2002;100(4):719-23. [pmid: 12383540].
212 Boreham MK, Richter HE, Kenton KS, et al. Anal incontinence in women presenting for gynecologic care: prevalence, risk factors, and impact upon quality of life. Am J Obstet Gynecol. May. 2005;192(5):1637-42. [pmid: 15902170].
213 Chen GD, Hu SW, Chen YC, et al. Prevalence and correlations of anal incontinence and constipation in Taiwanese women. Neurourol Urodyn. 2003;22(7):664-9. [pmid: 14595611].
214 MacArthur C, Glazener CM, Wilson PD, et al. Obstetric practice and faecal incontinence three months after delivery. Bjog. Jul. 2001;108(7):678-83. [pmid: 11467690].
215 Macarthur C, Glazener C, Lancashire R, et al. Faecal incontinence and mode of first and subsequent delivery: a six-year longitudinal study. Bjog. Aug. 2005;112(8):1075-82. [pmid: 16045521].
216 Quander CR, Morris MC, Melson J, et al. Prevalence of and factors associated with fecal incontinence in a large community study of older individuals. Am J Gastroenterol. Apr. 2005;100(4):905-9. [pmid: 15784039].
217 Kalantar JS, Howell S, Talley NJ. Prevalence of faecal incontinence and associated risk factors; an underdiagnosed problem in the Australian community?. Med J Aust. Jan 21. 2002;176(2):54-7. [pmid: 11936284].
218 Guise JM, Morris C, Osterweil P, et al. Incidence of fecal incontinence after childbirth. Obstet Gynecol. Feb. 2007;109(2 Pt 1):281-8. [pmid: 17267825].
219 Goode PS, Burgio KL, Halli AD, et al. Prevalence and correlates of fecal incontinence in community-dwelling older adults. J Am Geriatr Soc. Apr. 2005;53(4):629-35. [pmid: 15817009].
220 Nakayama H, Jorgensen HS, Pedersen PM, et al. Prevalence and risk factors of incontinence after stroke. The Copenhagen Stroke Study. Stroke. Jan. 1997;28(1):58-62. [pmid: 8996489].
221 Harari D, Coshall C, Rudd AG, et al. New-onset fecal incontinence after stroke: prevalence, natural history, risk factors, and impact. Stroke. Jan. 2003;34(1):144-50. [pmid: 12511766].
222 Brittain K, Perry S, Shaw C, et al. Isolated urinary, fecal, and double incontinence: Prevalence and degree of soiling in stroke survivors. J Am Geriatr Soc. Dec. 2006;54(12):1915-9. [pmid: 17198499].
223 Chassagne P, Landrin I, Neveu C, et al. Fecal incontinence in the institutionalized elderly: incidence, risk factors, and prognosis. Am J Med. Feb. 1999;106(2):185-90. [pmid: 10230748].
224 Johanson JF, Irizarry F, Doughty A. Risk factors for fecal incontinence in a nursing home population. J Clin Gastroenterol. Apr. 1997;24(3):156-60. [pmid: 9179734].
225 Bharucha AE, Zinsmeister AR, Locke GR, et al. Risk factors for fecal incontinence: a population-based study in women. Am J Gastroenterol. Jun. 2006;101(6):1305-12. [pmid: 16771954].
226 Abramov Y, Sand PK, Botros SM, et al. Risk factors for female anal incontinence: new insight through the Evanston-Northwestern twin sisters study. Obstet Gynecol. Oct. 2005;106(4):726-32. [pmid: 16199628].
227 Hojberg KE, Salvig JD, Winslow NA, et al. Flatus and faecal incontinence: prevalence and risk factors at 16 weeks of gestation. Bjog. Sep. 2000;107(9):1097-103. [pmid: 11002952].
228 Eason E, Labrecque M, Marcoux S, et al. Anal incontinence after childbirth. Cmaj. Feb 5. 2002;166(3):326-30. [pmid: 11868640]. [pmcid: 99311].
229 De Leeuw JW, Vierhout ME, Struijk PC, et al. Anal sphincter damage after vaginal delivery: functional outcome and risk factors for fecal incontinence. Acta Obstet Gynecol Scand. Sep. 2001;80(9):830-4. [pmid: 11531634].
230 Mahony R, Behan M, Daly L, et al. Internal anal sphincter defect influences continence outcome following obstetric anal sphincter injury. Am J Obstet Gynecol. Mar. 2007;196(3):217. e1–5. [pmid: 17346526].
231 Borello-France D, Burgio KL, Richter HE, et al. Fecal and urinary incontinence in primiparous women. Obstet Gynecol. Oct. 2006;108(4):863-72. [pmid: 17012447].
232 Faltin DL, Sangalli MR, Curtin F, et al. Prevalence of anal incontinence and other anorectal symptoms in women. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):117-20. discussion 21. [pmid: 11374509].
233 Schnelle JF, Traughber B, Sowell VA, et al. Prompted voiding treatment of urinary incontinence in nursing home patients. A behavior management approach for nursing home staff. J Am Geriatr Soc. Nov. 1989;37(11):1051-7. [pmid: 2809052].
234 Ouslander JG, Griffiths PC, McConnell E, et al. Functional incidental training: a randomized, controlled, crossover trial in Veterans Affairs nursing homes. J Am Geriatr Soc. Jul. 2005;53(7):1091-100. [pmid: 16108924].
235 Schnelle JF, Alessi CA, Simmons SF, et al. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. Sep. 2002;50(9):1476-83. [pmid: 12383143].
236 Jirovec MM, Templin T. Predicting success using individualized scheduled toileting for memory-impaired elders at home. Res Nurs Health. Feb. 2001;24(1):1-8. [pmid: 11260580].
237 Colling J, Ouslander J, Hadley BJ, et al. The effects of patterned urge-response toileting (PURT) on urinary incontinence among nursing home residents. J Am Geriatr Soc. Feb. 1992;40(2):135-41. [pmid: 1740597].
238 Schnelle JF, McNees P, Crooks V, et al. The use of a computer-based model to implement an incontinence management program. Gerontologist. Oct. 1995;35(5):656-65. [pmid: 8543223].
239 Wikander B, Ekelund P, Milsom I. An evaluation of multidisciplinary intervention governed by functional independence measure (FIMSM) in incontinent stroke patients. Scand J Rehabil Med. Mar. 1998;30(1):15-21. [pmid: 9526750].
240 Williams KS, Assassa RP, Cooper NJ, et al. Clinical and cost-effectiveness of a new nurse-led continence service: a randomised controlled trial. Br J Gen Pract. Sep. 2005;55(518):696-703. [pmid: 16176737]. [pmcid: 1464065].
241 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: episodes of incontinence and other urinary symptoms. J Aging Health. May. 2000;12(2):250-67. [pmid: 11010699].
242 Borrie MJ, Bawden M, Speechley M, et al. Interventions led by nurse continence advisers in the management of urinary incontinence: a randomized controlled trial. CMAJ. May 14. 2002;166(10):1267-73. [pmid: 12041843]. [pmcid: 111077].
243 Diokno AC, Sampselle CM, Herzog AR, et al. Prevention of urinary incontinence by behavioral modification program: a randomized, controlled trial among older women in the community. J Urol. Mar. 2004;171(3):1165-71. [pmid: 14767293].
244 Sampselle CM, Messer KL, Seng JS, et al. Learning outcomes of a group behavioral modification program to prevent urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):441-6. [pmid: 16237512].
245 Brown JS, Wing R, Barrett-Connor E, et al. Lifestyle intervention is associated with lower prevalence of urinary incontinence: the Diabetes Prevention Program. Diabetes Care. Feb. 2006;29(2):385-90. [pmid: 16443892]. [pmcid: 1557353].
246 Chiarelli P, Cockburn J. Promoting urinary continence in women after delivery: randomised controlled trial. Bmj. May 25. 2002;324(7348):1241. [pmid: 12028976]. [pmcid: 113274].
247 Reilly ET, Freeman RM, Waterfield MR, et al. Prevention of postpartum stress incontinence in primigravidae with increased bladder neck mobility: a randomised controlled trial of antenatal pelvic floor exercises. Bjog. Jan. 2002;109(1):68-76. [pmid: 11845813].
248 Chiarelli P, Murphy B, Cockburn J. Promoting urinary continence in postpartum women: 12-month follow-up data from a randomised controlled trial. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):99-105. discussion. [pmid: 15014936].
249 Meyer S, Hohlfeld P, Achtari C, et al. Pelvic floor education after vaginal delivery. Obstet Gynecol. May. 2001;97(5 Pt 1):673-7. [pmid: 11339914].
250 Labrecque M, Eason E, Marcoux S. Randomized trial of perineal massage during pregnancy: perineal symptoms three months after delivery. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):76-80. [pmid: 10649159].
251 Glazener CM, Herbison GP, Wilson PD, et al. Conservative management of persistent postnatal urinary and faecal incontinence: randomised controlled trial. BMJ. Sep 15. 2001;323(7313):593-6. [pmid: 11557703]. [pmcid: 55571].
252 Glazener CM, Herbison GP, MacArthur C, et al. Randomised controlled trial of conservative management of postnatal urinary and faecal incontinence: six year follow up. BMJ. Feb 12. 2005;330(7487):337. [pmid: 15615766]. [pmcid: 548727].
253 Sleep J, Grant A. Pelvic floor exercises in postnatal care. Midwifery. Dec. 1987;3(4):158-64. [pmid: 3320686].
254 Sampselle CM, Miller JM, Mims BL, et al. Effect of pelvic muscle exercise on transient incontinence during pregnancy and after birth. Obstet Gynecol. Mar. 1998;91(3):406-12. [pmid: 9491869].
255 Wille S, Sobottka A, Heidenreich A, et al. Pelvic floor exercises, electrical stimulation and biofeedback after radical prostatectomy: results of a prospective randomized trial. J Urol. Aug. 2003;170(2 Pt 1):490-3. [pmid: 12853806].
256 Yokoyama T, Nishiguchi J, Watanabe T, et al. Comparative study of effects of extracorporeal magnetic innervation versus electrical stimulation for urinary incontinence after radical prostatectomy. Urology. Feb. 2004;63(2):264-7. [pmid: 14972468].
257 Filocamo MT, Li Marzi V, Del Popolo G, et al. Effectiveness of early pelvic floor rehabilitation treatment for post-prostatectomy incontinence. Eur Urol. Nov. 2005;48(5):734-8. [pmid: 16002204].
258 Moore KN, Griffiths D, Hughton A. Urinary incontinence after radical prostatectomy: a randomized controlled trial comparing pelvic muscle exercises with or without electrical stimulation. BJU Int. Jan. 1999;83(1):57-65. [pmid: 10233453].
259 Mathewson-Chapman M. Pelvic muscle exercise/biofeedback for urinary incontinence after prostatectomy: an education program. J Cancer Educ. Winter. 1997;12(4):218-23. [pmid: 9440013].
260 Floratos DL, Sonke GS, Rapidou CA, et al. Biofeedback vs verbal feedback as learning tools for pelvic muscle exercises in the early management of urinary incontinence after radical prostatectomy. BJU Int. May. 2002;89(7):714-9. [pmid: 11966630].
261 Van Kampen M, De Weerdt W, Van Poppel H, et al. Effect of pelvic-floor re-education on duration and degree of incontinence after radical prostatectomy: a randomised controlled trial. Lancet. Jan 8. 2000;355(9198):98-102. [pmid: 10675166].
262 Bales GT, Gerber GS, Minor TX, et al. Effect of preoperative biofeedback/pelvic floor training on continence in men undergoing radical prostatectomy. Urology. Oct 1. 2000;56(4):627-30. [pmid: 11018619].
263 Porru D, Campus G, Caria A, et al. Impact of early pelvic floor rehabilitation after transurethral resection of the prostate. Neurourol Urodyn. 2001;20(1):53-9. [pmid: 11135382].
264 Franke JJ, Gilbert WB, Grier J, et al. Early post-prostatectomy pelvic floor biofeedback. J Urol. Jan. 2000;163(1):191-3. [pmid: 10604344].
265 Parekh AR, Feng MI, Kirages D, et al. The role of pelvic floor exercises on post-prostatectomy incontinence. J Urol. Jul. 2003;170(1):130-3. [pmid: 12796664].
266 Dorey G, Speakman M, Feneley R, et al. Pelvic floor exercises for treating post-micturition dribble in men with erectile dysfunction: a randomized controlled trial. Urol Nurs 2004 Dec; 24(6):490–7, 512.
267 Dumoulin C, Lemieux MC, Bourbonnais D, et al. Physiotherapy for persistent postnatal stress urinary incontinence: a randomized controlled trial. Obstet Gynecol. Sep. 2004;104(3):504-10. [pmid: 15339760].
268 Goode PS, Burgio KL, Locher JL, et al. Effect of behavioral training with or without pelvic floor electrical stimulation on stress incontinence in women: a randomized controlled trial. JAMA. Jul 16. 2003;290(3):345-52. [pmid: 12865375].
269 Wyman JF, Fantl JA, McClish DK, et al. Comparative efficacy of behavioral interventions in the management of female urinary incontinence. Continence Program for Women Research Group. Am J Obstet Gynecol. Oct. 1998;179(4):999-1007. [pmid: 9790388].
270 Theofrastous JP, Wyman JF, Bump RC, et al. Effects of pelvic floor muscle training on strength and predictors of response in the treatment of urinary incontinence. Neurourol Urodyn. 2002;21(5):486-90. [pmid: 12232886].
271 Alewijnse D, Metsemakers JF, Mesters IE, et al. Effectiveness of pelvic floor muscle exercise therapy supplemented with a health education program to promote long-term adherence among women with urinary incontinence. Neurourol Urodyn. 2003;22(4):284-95. [pmid: 12808702].
272 Aukee P, Immonen P, Laaksonen DE, et al. The effect of home biofeedback training on stress incontinence. Acta Obstet Gynecol Scand. Oct. 2004;83(10):973-7. [pmid: 15453897].
273 Bergman A, Matthews L, Ballard CA. Bladder training after surgery for stress urinary incontinence: is it necessary?. Obstet Gynecol. Dec. 1987;70(6):909-12. [pmid: 3684128].
274 Wang AC, Wang YY, Chen MC. Single-blind, randomized trial of pelvic floor muscle training, biofeedback-assisted pelvic floor muscle training, and electrical stimulation in the management of overactive bladder. Urology. Jan. 2004;63(1):61-6. [pmid: 14751349].
275 Bo K, Kvarstein B, Nygaard I. Lower urinary tract symptoms and pelvic floor muscle exercise adherence after 15 years. Obstet Gynecol. May. 2005;105(5 Pt 1):999-1005. [pmid: 15863536].
276 Elser DM, Wyman JF, McClish DK, et al. The effect of bladder training, pelvic floor muscle training, or combination training on urodynamic parameters in women with urinary incontinence. Continence Program for Women Research Group. Neurourol Urodyn. 1999;18(5):427-36. [pmid: 10494113].
277 Tibaek S, Gard G, Jensen R. Pelvic floor muscle training is effective in women with urinary incontinence after stroke: a randomised, controlled and blinded study. Neurourol Urodyn. 2005;24(4):348-57. [pmid: 15791633].
278 Subak LL, Quesenberry CP, Posner SF, et al. The effect of behavioral therapy on urinary incontinence: a randomized controlled trial. Obstet Gynecol. Jul. 2002;100(1):72-8. [pmid: 12100806].
279 Goode PS, Burgio KL, Locher JL, et al. Urodynamic changes associated with behavioral and drug treatment of urge incontinence in older women. J Am Geriatr Soc. May. 2002;50(5):808-16. [pmid: 12028165].
280 Lagro-Janssen AL, Debruyne FM, Smits AJ, et al. The effects of treatment of urinary incontinence in general practice. Fam Pract. Sep. 1992;9(3):284-9. [pmid: 1459383].
281 Fantl JA, Wyman JF, McClish DK, et al. Efficacy of bladder training in older women with urinary incontinence. JAMA. Feb 6. 1991;265(5):609-13. [pmid: 1987410].
282 Dougherty MC, Dwyer JW, Pendergast JF, et al. A randomized trial of behavioral management for continence with older rural women. Res Nurs Health. Feb. 2002;25(1):3-13. [pmid: 11807915].
283 Burgio KL, Goode PS, Locher JL, et al. Behavioral training with and without biofeedback in the treatment of urge incontinence in older women: a randomized controlled trial. JAMA. Nov 13. 2002;288(18):2293-9. [pmid: 12425706].
284 Wyman JF, Fantl JA, McClish DK, et al. Quality of life following bladder training in older women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):223-9. [pmid: 9449301].
285 Yoon HS, Song HH, Ro YJ. A comparison of effectiveness of bladder training and pelvic muscle exercise on female urinary incontinence. Int J Nurs Stud. Jan. 2003;40(1):45-50. [pmid: 12550149].
286 Janssen CC, Lagro-Janssen AL, Felling AJ. The effects of physiotherapy for female urinary incontinence: individual compared with group treatment. BJU Int. Feb. 2001;87(3):201-6. [pmid: 11167642].
287 Nygaard IE, Kreder KJ, Lepic MM, et al. Efficacy of pelvic floor muscle exercises in women with stress, urge, and mixed urinary incontinence. Am J Obstet Gynecol. Jan. 1996;174(1 Pt 1):120-5. [pmid: 8571994].
288 Aksac B, Aki S, Karan A, et al. Biofeedback and pelvic floor exercises for the rehabilitation of urinary stress incontinence. Gynecol Obstet Invest. 2003;56(1):23-7. [pmid: 12867764].
289 Burns PA, Pranikoff K, Nochajski TH, et al. A comparison of effectiveness of biofeedback and pelvic muscle exercise treatment of stress incontinence in older community-dwelling women. J Gerontol. Jul. 1993;48(4):M167-74. [pmid: 8315230].
290 Kim JI. Continence efficacy intervention program for community residing women with stress urinary incontinence in Japan. Public Health Nurs. Jan–Feb. 2001;18(1):64-72. [pmid: 11251875].
291 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: health-related quality of life. J Aging Health. Aug. 2000;12(3):301-17. [pmid: 11067699].
292 Lagro-Janssen TL, Debruyne FM, Smits AJ, et al. Controlled trial of pelvic floor exercises in the treatment of urinary stress incontinence in general practice. Br J Gen Pract. Nov. 1991;41(352):445-9. [pmid: 1807303]. [pmcid: 1371786].
293 Smith JJ 3rd. Intravaginal stimulation randomized trial. J Urol. Jan. 1996;155(1):127-30. [pmid: 7490809].
294 Sand PK, Richardson DA, Staskin DR, et al. Pelvic floor electrical stimulation in the treatment of genuine stress incontinence: a multicenter, placebo-controlled trial. Am J Obstet Gynecol. Jul. 1995;173(1):72-9. [pmid: 7631730].
295 Luber KM, Wolde-Tsadik G. Efficacy of functional electrical stimulation in treating genuine stress incontinence: a randomized clinical trial. Neurourol Urodyn. 1997;16(6):543-51. [pmid: 9353803].
296 Fujishiro T, Enomoto H, Ugawa Y, et al. Magnetic stimulation of the sacral roots for the treatment of stress incontinence: an investigational study and placebo controlled trial. J Urol. Oct. 2000;164(4):1277-9. [pmid: 10992380].
297 Pages IH, Jahr S, Schaufele MK, et al. Comparative analysis of biofeedback and physical therapy for treatment of urinary stress incontinence in women. Am J Phys Med Rehabil. Jul. 2001;80(7):494-502. [pmid: 11421517].
298 But I. Conservative treatment of female urinary incontinence with functional magnetic stimulation. Urology. Mar. 2003;61(3):558-61. [pmid: 12639647].
299 Bo K, Talseth T, Holme I. Single blind, randomised controlled trial of pelvic floor exercises, electrical stimulation, vaginal cones, and no treatment in management of genuine stress incontinence in women. BMJ. Feb 20. 1999;318(7182):487-93. [pmid: 10024253]. [pmcid: 27740].
300 Yamanishi T, Yasuda K, Sakakibara R, et al. Pelvic floor electrical stimulation in the treatment of stress incontinence: an investigational study and a placebo controlled double-blind trial. J Urol. Dec. 1997;158(6):2127-31. [pmid: 9366328].
301 Yamanishi T, Yasuda K, Sakakibara R, et al. Randomized, double-blind study of electrical stimulation for urinary incontinence due to detrusor overactivity. Urology. Mar. 2000;55(3):353-7. [pmid: 10699609].
302 Brubaker L, Benson JT, Bent A, et al. Transvaginal electrical stimulation for female urinary incontinence. Am J Obstet Gynecol. Sep. 1997;177(3):536-40. [pmid: 9322620].
303 Borawski KM, Foster RT, Webster GD, et al. Predicting implantation with a neuromodulator using two different test stimulation techniques: A prospective randomized study in urge incontinent women. Neurourol Urodyn. 2007;26(1):14-8. [pmid: 17123297].
304 Indrekvam S, Sandvik H, Hunskaar S. A Norwegian national cohort of 3198 women treated with home-managed electrical stimulation for urinary incontinence—effectiveness and treatment results. Scand J Urol Nephrol. Feb. 2001;35(1):32-9. [pmid: 11291684].
305 Schmidt RA, Jonas U, Oleson KA, et al. Sacral nerve stimulation for treatment of refractory urinary urge incontinence. Sacral Nerve Stimulation Study Group. J Urol. Aug. 1999;162(2):352-7. [pmid: 10411037].
306 Weil EH, Ruiz-Cerda JL, Eerdmans PH, et al. Sacral root neuromodulation in the treatment of refractory urinary urge incontinence: a prospective randomized clinical trial. Eur Urol. Feb. 2000;37(2):161-71. [pmid: 10705194].
307 Corcos J, Collet JP, Shapiro S, et al. Multicenter randomized clinical trial comparing surgery and collagen injections for treatment of female stress urinary incontinence. Urology. May. 2005;65(5):898-904. [pmid: 15882720].
308 Strasser H, Marksteiner R, Margreiter E, et al. Autologous myoblasts and fibroblasts versus collagen for treatment of stress urinary incontinence in women: a randomised controlled trial. Lancet. Jun 30. 2007;369(9580):2179-86. [pmid: 17604800].
309 Bano F, Barrington JW, Dyer R. Comparison between porcine dermal implant (Permacol) and silicone injection (Macroplastique) for urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):147-50. discussion 50. [pmid: 15378234].
310 Schulz JA, Nager CW, Stanton SL, et al. Bulking agents for stress urinary incontinence: short-term results and complications in a randomized comparison of periurethral and transurethral injections. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):261-5. [pmid: 15517671].
311 Nygaard I. Prevention of exercise incontinence with mechanical devices. J Reprod Med. Feb. 1995;40(2):89-94. [pmid: 7738934].
312 Thyssen H, Bidmead J, Lose G, et al. A new intravaginal device for stress incontinence in women. BJU Int. Dec. 2001;88(9):889-92. [pmid: 11851609].
313 Robinson H, Schulz J, Flood C, et al. A randomized controlled trial of the NEAT expandable tip continence device. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):199-203. discussion. [pmid: 12955343].
314 Nielsen KK, Walter S, Maegaard E, et al. The urethral plug II: an alternative treatment in women with genuine urinary stress incontinence. Br J Urol. Oct. 1993;72(4):428-32. [pmid: 8261298].
315 Seo JT, Yoon H, Kim YH. A randomized prospective study comparing new vaginal cone and FES-Biofeedback. Yonsei Med J. Oct 31. 2004;45(5):879-84. [pmid: 15515199].
316 Laycock J, Brown J, Cusack C, et al. Pelvic floor reeducation for stress incontinence: comparing three methods. Br J Community Nurs. May. 2001;6(5):230-7. [pmid: 11893948].
317 Chancellor MB, Bennett C, Simoneau AR, et al. Sphincteric stent versus external sphincterotomy in spinal cord injured men: prospective randomized multicenter trial. J Urol. Jun. 1999;161(6):1893-8. [pmid: 10332461].
318 Moore KN, Schieman S, Ackerman T, et al. Assessing comfort, safety, and patient satisfaction with three commonly used penile compression devices. Urology. Jan. 2004;63(1):150-4. [pmid: 14751370].
319 Kaya H, Sezik M, Ozbasar D, et al. Intrafascial versus extrafascial abdominal hysterectomy: effects on urinary urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):171-4. [pmid: 15167995].
320 Gimbel H, Zobbe V, Andersen BM, et al. Randomised controlled trial of total compared with subtotal hysterectomy with one-year follow up results. Bjog. Dec. 2003;110(12):1088-98. [pmid: 14664880].
321 Costantini E, Zucchi A, Giannantoni A, et al. Must colposuspension be associated with sacropexy to prevent postoperative urinary incontinence?. Eur Urol. Mar. 2007;51(3):788-94. [pmid: 17011699].
322 Colombo M, Maggioni A, Zanetta G, et al. Prevention of postoperative urinary stress incontinence after surgery for genitourinary prolapse. Obstet Gynecol. Feb. 1996;87(2):266-71. [pmid: 8559537].
323 Choe JM, Ogan K, Battino BS. Antimicrobial mesh versus vaginal wall sling: a comparative outcomes analysis. J Urol. Jun. 2000;163(6):1829-34. [pmid: 10799192].
324 Kuo HC. Comparison of video urodynamic results after the pubovaginal sling procedure using rectus fascia and polypropylene mesh for stress urinary incontinence. J Urol. Jan. 2001;165(1):163-8. [pmid: 11125388].
325 Adamiak A, Milart P, Skorupski P, et al. The efficacy and safety of the tension-free vaginal tape procedure do not depend on the method of analgesia. Eur Urol. Jul. 2002;42(1):29-33. [pmid: 12121726].
326 Arunkalaivanan AS, Barrington JW. Randomized trial of porcine dermal sling (Pelvicol implant) vs. tension-free vaginal tape (TVT) in the surgical treatment of stress incontinence: a questionnaire-based study. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):17-23. discussion 1–2. [pmid: 12601511].
327 Rechberger T, Rzezniczuk K, Skorupski P, et al. A randomized comparison between monofilament and multifilament tapes for stress incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):432-6. [pmid: 14677007].
328 Rafii A, Paoletti X, Haab F, et al. Tension-free vaginal tape and associated procedures: a case control study. Eur Urol. Mar. 2004;45(3):356-61. [pmid: 15036683].
329 deTayrac R, Deffieux X, Droupy S, et al. A prospective randomized trial comparing tension-free vaginal tape and transobturator suburethral tape for surgical treatment of stress urinary incontinence. Am J Obstet Gynecol. Mar. 2004;190(3):602-8. [pmid: 15041987].
330 Meschia M, Pifarotti P, Spennacchio M, et al. A randomized comparison of tension-free vaginal tape and endopelvic fascia plication in women with genital prolapse and occult stress urinary incontinence. Am J Obstet Gynecol. Mar. 2004;190(3):609-13. [pmid: 15041988].
331 Valpas A, Kivela A, Penttinen J, et al. Tension-free vaginal tape and laparoscopic mesh colposuspension for stress urinary incontinence. Obstet Gynecol. Jul. 2004;104(1):42-9. [pmid: 15228999].
332 Abdel-Fattah M, Barrington JW, Arunkalaivanan AS. Pelvicol pubovaginal sling versus tension-free vaginal tape for treatment of urodynamic stress incontinence: a prospective randomized three-year follow-up study. Eur Urol. Nov. 2004;46(5):629-35. [pmid: 15474274].
333 Cholhan HJ, Lotze PM. Voiding function after a modified no-tension pubovaginal sling. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):249-56. [pmid: 15517669].
334 Lim YN, Muller R, Corstiaans A, et al. Suburethral slingplasty evaluation study in North Queensland, Australia: the SUSPEND trial. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):52-9. [pmid: 15730366].
335 Andonian S, Chen T, St-Denis B, et al. Randomized clinical trial comparing suprapubic arch sling (SPARC) and tension-free vaginal tape (TVT): one-year results. Eur Urol. Apr. 2005;47(4):537-41. [pmid: 15774255].
336 Tseng LH, Wang AC, Lin YH, et al. Randomized comparison of the suprapubic arc sling procedure vs tension-free vaginal taping for stress incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):230-5. [pmid: 15875240].
337 Maher CF, O'Reilly BA, Dwyer PL, et al. Pubovaginal sling versus transurethral Macroplastique for stress urinary incontinence and intrinsic sphincter deficiency: a prospective randomised controlled trial. BJOG. Jun. 2005;112(6):797-801. [pmid: 15924540].
338 Wadie BS, Edwan A, Nabeeh AM. Autologous fascial sling vs polypropylene tape at short-term followup: a prospective randomized study. J Urol. Sep. 2005;174(3):990-3. [pmid: 16094020].
339 David-Montefiore E, Frobert JL, Grisard-Anaf M, et al. Peri-operative complications and pain after the suburethral sling procedure for urinary stress incontinence: a French prospective randomised multicentre study comparing the retropubic and transobturator routes. Eur Urol. Jan. 2006;49(1):133-8. [pmid: 16310932].
340 Meschia M, Pifarotti P, Bernasconi F, et al. Tension-free vaginal tape (TVT) and intravaginal slingplasty (IVS) for stress urinary incontinence: a multicenter randomized trial. Am J Obstet Gynecol. Nov. 2006;195(5):1338-42. [pmid: 16769016].
341 Lord HE, Taylor JD, Finn JC, et al. A randomized controlled equivalence trial of short-term complications and efficacy of tension-free vaginal tape and suprapubic urethral support sling for treating stress incontinence. BJU Int. Aug. 2006;98(2):367-76. [pmid: 16879679].
342 Darai E, Frobert JL, Grisard-Anaf M, et al. Functional results after the suburethral sling procedure for urinary stress incontinence: a prospective randomized multicentre study comparing the retropubic and transobturator routes. Eur Urol. Mar. 2007;51(3):795-801. discussion -2. [pmid: 17010507].
343 Albo ME, Richter HE, Brubaker L, et al. Burch colposuspension versus fascial sling to reduce urinary stress incontinence. N Engl J Med. May 24. 2007;356(21):2143-55. [pmid: 17517855].
344 Bai SW, Sohn WH, Chung DJ, et al. Comparison of the efficacy of Burch colposuspension, pubovaginal sling, and tension-free vaginal tape for stress urinary incontinence. Int J Gynaecol Obstet. Dec. 2005;91(3):246-51. [pmid: 16242695].
345 Bergman A, Ballard CA, Koonings PP. Comparison of three different surgical procedures for genuine stress incontinence: prospective randomized study. Am J Obstet Gynecol. May. 1989;160(5 Pt 1):1102-6. [pmid: 2729386].
346 Cheon WC, Mak JH, Liu JY. Prospective randomised controlled trial comparing laparoscopic and open colposuspension. Hong Kong Med J. Feb. 2003;9(1):10-4. [pmid: 12547950].
347 Colombo M, Scalambrino S, Maggioni A, et al. Burch colposuspension versus modified Marshall-Marchetti-Krantz urethropexy for primary genuine stress urinary incontinence: a prospective, randomized clinical trial. Am J Obstet Gynecol. Dec. 1994;171(6):1573-9. [pmid: 7802070].
348 Colombo M, Milani R, Vitobello D, et al. A randomized comparison of Burch colposuspension and abdominal paravaginal defect repair for female stress urinary incontinence. Am J Obstet Gynecol. Jul. 1996;175(1):78-84. [pmid: 8694079].
349 Culligan PJ, Goldberg RP, Sand PK. A randomized controlled trial comparing a modified Burch procedure and a suburethral sling: long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):229-33. discussion 33. [pmid: 14530832].
350 Fatthy H, El Hao M, Samaha I, et al. Modified Burch colposuspension: laparoscopy versus laparotomy. J Am Assoc Gynecol Laparosc. Feb. 2001;8(1):99-106. [pmid: 11172123].
351 Gilja I, Puskar D, Mazuran B, et al. Comparative analysis of bladder neck suspension using Raz, Burch and transvaginal Burch procedures. A 3-year randomized prospective study. Eur Urol. 1998;33(3):298-302. [pmid: 9555556].
352 Ishiko O, Hirai K, Sumi T, et al. Hormone replacement therapy plus pelvic floor muscle exercise for postmenopausal stress incontinence. A randomized, controlled trial. J Reprod Med. Mar. 2001;46(3):213-20. [pmid: 11304861].
353 Kammerer-Doak DN, Dorin MH, Rogers RG, et al. A randomized trial of burch retropubic urethropexy and anterior colporrhaphy for stress urinary incontinence. Obstet Gynecol. Jan. 1999;93(1):75-8. [pmid: 9916960].
354 Lalos O, Berglund AL, Bjerle P. Urodynamics in women with stress incontinence before and after surgery. Eur J Obstet Gynecol Reprod Biol. Mar. 1993;48(3):197-205. [pmid: 8335138].
355 Liapis A, Bakas P, Creatsas G. Burch colposuspension and tension-free vaginal tape in the management of stress urinary incontinence in women. Eur Urol. Apr. 2002;41(4):469-73. [pmid: 12074820].
356 Persson J, Wolner-Hanssen P. Laparoscopic Burch colposuspension for stress urinary incontinence: a randomized comparison of one or two sutures on each side of the urethra. Obstet Gynecol. Jan. 2000;95(1):151-5. [pmid: 10636519].
357 Quadri G, Magatti F, Belloni C, et al. Marshall-Marchetti-Krantz urethropexy and Burch colposuspension for stress urinary incontinence in women with low pressure and hypermobility of the urethra: early results of a prospective randomized clinical trial. Am J Obstet Gynecol. Jul. 1999;181(1):12-8. [pmid: 10411835].
358 Sand PK, Winkler H, Blackhurst DW, et al. A prospective randomized study comparing modified Burch retropubic urethropexy and suburethral sling for treatment of genuine stress incontinence with low-pressure urethra. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):30-4. [pmid: 10649153].
359 Su TH, Wang KG, Hsu CY, et al. Prospective comparison of laparoscopic and traditional colposuspensions in the treatment of genuine stress incontinence. Acta Obstet Gynecol Scand. Jul. 1997;76(6):576-82. [pmid: 9246967].
360 Ustun Y, Engin-Ustun Y, Gungor M, et al. Tension-free vaginal tape compared with laparoscopic Burch urethropexy. J Am Assoc Gynecol Laparosc. Aug. 2003;10(3):386-9. [pmid: 14567818].
361 Zullo F, Palomba S, Piccione F, et al. Laparoscopic Burch colposuspension: a randomized controlled trial comparing two transperitoneal surgical techniques. Obstet Gynecol. Nov. 2001;98(5 Pt 1):783-8. [pmid: 11704169].
362 Colombo M, Vitobello D, Proietti F, et al. Randomised comparison of Burch colposuspension versus anterior colporrhaphy in women with stress urinary incontinence and anterior vaginal wall prolapse. Bjog. Apr. 2000;107(4):544-51. [pmid: 10759276].
363 Dessole S, Rubattu G, Ambrosini G, et al. Efficacy of low-dose intravaginal estriol on urogenital aging in postmenopausal women. Menopause. Jan–Feb. 2004;11(1):49-56. [pmid: 14716182].
364 Holtedahl K, Verelst M, Schiefloe A. A population based, randomized, controlled trial of conservative treatment for urinary incontinence in women. Acta Obstet Gynecol Scand. Jul. 1998;77(6):671-7. [pmid: 9688247].
365 Hendrix SL, Cochrane BB, Nygaard IE, et al. Effects of estrogen with and without progestin on urinary incontinence. Jama. Feb 23. 2005;293(8):935-48. [pmid: 15728164].
366 Steinauer JE, Waetjen LE, Vittinghoff E, et al. Postmenopausal hormone therapy: does it cause incontinence?. Obstet Gynecol. Nov. 2005;106(5 Pt 1):940-5. [pmid: 16260510]. [pmcid: 1557396].
367 Goldstein SR, Johnson S, Watts NB, et al. Incidence of urinary incontinence in postmenopausal women treated with raloxifene or estrogen. Menopause. Mar. 2005;12(2):160-4. [pmid: 15772563].
368 Akhila V, Pratapkumar. A comparison of transdermal and oral HRT for menopausal symptom control. Int J Fertil Womens Med. Mar–Apr. 2006;51(2):64-9. [pmid: 16881381].
369 Rufford J, Hextall A, Cardozo L, et al. A double-blind placebo-controlled trial on the effects of 25 mg estradiol implants on the urge syndrome in postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):78-83. [pmid: 12851747].
370 Mikkelsen AL, Felding C, Clausen HV. Clinical effects of preoperative oestradiol treatment before vaginal repair operation. A double-blind, randomized trial. Gynecol Obstet Invest. 1995;40(2):125-8. [pmid: 8575690].
371 Bliss DZ, Jung HJ, Savik K, et al. Supplementation with dietary fiber improves fecal incontinence. Nurs Res. Jul–Aug. 2001;50(4):203-13. [pmid: 11480529].
372 Fynes MM, Marshall K, Cassidy M, et al. A prospective, randomized study comparing the effect of augmented biofeedback with sensory biofeedback alone on fecal incontinence after obstetric trauma. Dis Colon Rectum. Jun. 1999;42(6):753-8. discussion 8–61. [pmid: 10378599].
373 Miner PB, Donnelly TC, Read NW. Investigation of mode of action of biofeedback in treatment of fecal incontinence. Dig Dis Sci. Oct. 1990;35(10):1291-8. [pmid: 2209296].
374 Byrne CM, Pager CK, Rex J, et al. Assessment of quality of life in the treatment of patients with neuropathic fecal incontinence. Dis Colon Rectum. Nov. 2002;45(11):1431-6. [pmid: 12432287].
375 Solomon MJ, Pager CK, Rex J, et al. Randomized, controlled trial of biofeedback with anal manometry, transanal ultrasound, or pelvic floor retraining with digital guidance alone in the treatment of mild to moderate fecal incontinence. Dis Colon Rectum. Jun. 2003;46(6):703-10. [pmid: 12794569].
376 Norton C, Chelvanayagam S, Wilson-Barnett J, et al. Randomized controlled trial of biofeedback for fecal incontinence. Gastroenterology. Nov. 2003;125(5):1320-9. [pmid: 14598248].
377 Leroi AM, Parc Y, Lehur PA, et al. Efficacy of sacral nerve stimulation for fecal incontinence: results of a multicenter double-blind crossover study. Ann Surg. Nov. 2005;242(5):662-9. [pmid: 16244539]. [pmcid: 1409867].
378 Hallgren T, Fasth S, Delbro DS, et al. Loperamide improves anal sphincter function and continence after restorative proctocolectomy. Dig Dis Sci. Dec. 1994;39(12):2612-8. [pmid: 7995187].
379 Kneebone A, Mameghan H, Bolin T, et al. Effect of oral sucralfate on late rectal injury associated with radiotherapy for prostate cancer: A double-blind, randomized trial. Int J Radiat Oncol Biol Phys. Nov 15. 2004;60(4):1088-97. [pmid: 15519779].
380 Mentes BB, Irkorucu O, Akin M, et al. Comparison of botulinum toxin injection and lateral internal sphincterotomy for the treatment of chronic anal fissure. Dis Colon Rectum. Feb. 2003;46(2):232-7. [pmid: 12576897].
381 Fernando RJ, Sultan AH, Kettle C, et al. Repair techniques for obstetric anal sphincter injuries: a randomized controlled trial. Obstet Gynecol. Jun. 2006;107(6):1261-8. [pmid: 16738150].
382 Garcia V, Rogers RG, Kim SS, et al. Primary repair of obstetric anal sphincter laceration: a randomized trial of two surgical techniques. Am J Obstet Gynecol. May. 2005;192(5):1697-701. [pmid: 15902180].
383 Williams A, Adams EJ, Tincello DG, et al. How to repair an anal sphincter injury after vaginal delivery: results of a randomised controlled trial. Bjog. Feb. 2006;113(2):201-7. [pmid: 16411999].
384 Tjandra JJ, Han WR, Goh J, et al. Direct repair vs. overlapping sphincter repair: a randomized, controlled trial. Dis Colon Rectum. Jul. 2003;46(7):937-42. discussion 42–3. [pmid: 12847369].
385 Faltin DL, Boulvain M, Floris LA, et al. Diagnosis of anal sphincter tears to prevent fecal incontinence: a randomized controlled trial. Obstet Gynecol. Jul. 2005;106(1):6-13. [pmid: 15994610].
386 Dannecker C, Hillemanns P, Strauss A, et al. Episiotomy and perineal tears presumed to be imminent: the influence on the urethral pressure profile, analmanometric and other pelvic floor findings—follow-up study of a randomized controlled trial. Acta Obstet Gynecol Scand. Jan. 2005;84(1):65-71. [pmid: 15603570].
387 Sartore A, De Seta F, Maso G, et al. The effects of mediolateral episiotomy on pelvic floor function after vaginal delivery. Obstet Gynecol. Apr. 2004;103(4):669-73. [pmid: 15051557].
388 Hannah ME, Hannah WJ, Hodnett ED, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. Jama. Apr 10. 2002;287(14):1822-31. [pmid: 11939868].
389 Hannah ME, Whyte H, Hannah WJ, et al. Maternal outcomes at 2 years after planned cesarean section versus planned vaginal birth for breech presentation at term: the international randomized Term Breech Trial. Am J Obstet Gynecol. Sep. 2004;191(3):917-27. [pmid: 15467565].
390 Fitzpatrick M, Harkin R, McQuillan K, et al. A randomised clinical trial comparing the effects of delayed versus immediate pushing with epidural analgesia on mode of delivery and faecal continence. Bjog. Dec. 2002;109(12):1359-65. [pmid: 12504971].
391 Johanson RB, Heycock E, Carter J, et al. Maternal and child health after assisted vaginal delivery: five-year follow up of a randomised controlled study comparing forceps and ventouse. Br J Obstet Gynaecol. Jun. 1999;106(6):544-9. [pmid: 10426611].
392 Fitzpatrick M, Behan M, O'Connell PR, et al. Randomised clinical trial to assess anal sphincter function following forceps or vacuum assisted vaginal delivery. Bjog. Apr. 2003;110(4):424-9. [pmid: 12699806].
393 Sultan AH, Johanson RB, Carter JE. Occult anal sphincter trauma following randomized forceps and vacuum delivery. Int J Gynaecol Obstet. May. 1998;61(2):113-9. [pmid: 9639214].
394 Hetzer FH, Demartines N, Handschin AE, et al. Stapled vs excision hemorrhoidectomy: long-term results of a prospective randomized trial. Arch Surg. Mar. 2002;137(3):337-40. [pmid: 11888463].
395 Konsten J, Baeten CG. Hemorrhoidectomy vs. Lord's method: 17-year follow-up of a prospective, randomized trial. Dis Colon Rectum. Apr. 2000;43(4):503-6. [pmid: 10789746].
396 Jayne DG, Botterill I, Ambrose NS, et al. Randomized clinical trial of Ligasure versus conventional diathermy for day-case haemorrhoidectomy. Br J Surg. Apr. 2002;89(4):428-32. [pmid: 11952582].
397 Galizia G, Lieto E, Castellano P, et al. Lateral internal sphincterotomy together with haemorrhoidectomy for treatment of haemorrhoids: a randomised prospective study. Eur J Surg. Mar. 2000;166(3):223-8. [pmid: 10755337].
398 Lawes DA, Palazzo FF, Francis DL, et al. One year follow up of a randomized trial comparing Ligasure with open haemorrhoidectomy. Colorectal Dis. Jul. 2004;6(4):233-5. [pmid: 15206964].
399 Filingeri V, Gravante G, Baldessari E, et al. Prospective randomized trial of submucosal hemorrhoidectomy with radiofrequency bistoury vs. conventional Parks' operation. Tech Coloproctol. Mar. 2004;8(1):31-6. [pmid: 15057587].
400 Johannsson HO, Pahlman L, Graf W. Randomized clinical trial of the effects on anal function of Milligan-Morgan versus Ferguson haemorrhoidectomy. Br J Surg. Oct. 2006;93(10):1208-14. [pmid: 16952213].
401 Khan S, Pawlak SE, Eggenberger JC, et al. Surgical treatment of hemorrhoids: prospective, randomized trial comparing closed excisional hemorrhoidectomy and the Harmonic Scalpel technique of excisional hemorrhoidectomy. Dis Colon Rectum. Jun. 2001;44(6):845-9. [pmid: 11391146].
402 van Tets WF, Kuijpers JH, Tran7 K, et al. Influence of Parks' anal retractor on anal sphincter pressures. Dis Colon Rectum. Sep. 1997;40(9):1042-5. [pmid: 9293932].
403 Ho KS, Ho YH. Randomized clinical trial comparing oral nifedipine with lateral anal sphincterotomy and tailored sphincterotomy in the treatment of chronic anal fissure. Br J Surg. Apr. 2005;92(4):403-8. [pmid: 15739214].
404 Tankova L, Yoncheva K, Muhtarov M, et al. Topical mononitrate treatment in patients with anal fissure. Aliment Pharmacol Ther. Jan. 2002;16(1):101-3. [pmid: 11856083].
405 De Nardi P, Ortolano E, Radaelli G, et al. Comparison of glycerine trinitrate and botulinum toxin-a for the treatment of chronic anal fissure: long-term results. Dis Colon Rectum. Apr. 2006;49(4):427-32. [pmid: 16456637].
406 Luukkonen P, Mikkonen U, Jarvinen H. Abdominal rectopexy with sigmoidectomy vs. rectopexy alone for rectal prolapse: a prospective, randomized study. Int J Colorectal Dis. Dec. 1992;7(4):219-22. [pmid: 1338091].
407 Racalbuto A, Aliotta I, Corsaro G, et al. Hemorrhoidal stapler prolapsectomy vs. Milligan-Morgan hemorrhoidectomy: a long-term randomized trial. Int J Colorectal Dis. May. 2004;19(3):239-44. [pmid: 14605834].
408 Novell JR, Osborne MJ, Winslet MC, et al. Prospective randomized trial of Ivalon sponge versus sutured rectopexy for full-thickness rectal prolapse. Br J Surg. Jun. 1994;81(6):904-6. [pmid: 8044618].
409 Solomon MJ, Young CJ, Eyers AA, et al. Randomized clinical trial of laparoscopic versus open abdominal rectopexy for rectal prolapse. Br J Surg. Jan. 2002;89(1):35-9. [pmid: 11851660].
410 Galili Y, Rabau M. Comparison of polyglycolic acid and polypropylene mesh for rectopexy in the treatment of rectal prolapse. Eur J Surg. Jun. 1997;163(6):445-8. [pmid: 9231856].
411 Boccasanta P, Venturi M, Barbieri S, et al. Impact of new technologies on the clinical and functional outcome of Altemeier's procedure: a randomized, controlled trial. Dis Colon Rectum. May. 2006;49(5):652-60. [pmid: 16575620].
412 Boccasanta P, Rosati R, Venturi M, et al. Comparison of laparoscopic rectopexy with open technique in the treatment of complete rectal prolapse: clinical and functional results. Surg Laparosc Endosc. Dec. 1998;8(6):460-5. [pmid: 9864116].
413 Deen KI, Grant E, Billingham C, et al. Abdominal resection rectopexy with pelvic floor repair versus perineal rectosigmoidectomy and pelvic floor repair for full-thickness rectal prolapse. Br J Surg. Feb. 1994;81(2):302-4. [pmid: 8156369].
414 Sayfan J, Pinho M, Alexander-Williams J, et al. Sutured posterior abdominal rectopexy with sigmoidectomy compared with Marlex rectopexy for rectal prolapse. Br J Surg. Feb. 1990;77(2):143-5. [pmid: 2317672].
415 Schouten WR, van Vroonhoven TJ. Treatment of anorectal abscess with or without primary fistulectomy. Results of a prospective randomized trial. Dis Colon Rectum. Jan. 1991;34(1):60-3. [pmid: 1991422].
416 Singer M, Cintron J, Nelson R, et al. Treatment of fistulas-in-ano with fibrin sealant in combination with intra-adhesive antibiotics and/or surgical closure of the internal fistula opening. Dis Colon Rectum. Apr. 2005;48(4):799-808. [pmid: 15785883].
417 Zimmerman DD, Gosselink MP, Hop WC, et al. Impact of two different types of anal retractor on fecal continence after fistula repair: a prospective, randomized, clinical trial. Dis Colon Rectum. Dec. 2003;46(12):1674-9. [pmid: 14668594].
418 Ho KS, Ho YH. Controlled, randomized trial of island flap anoplasty for treatment of transsphincteric fistula-in-ano: early results. Tech Coloproctol. Jul. 2005;9(2):166-8. [pmid: 16007352].
419 Libertiny G, Knight JS, Farouk R. Randomised trial of topical 0.2% glyceryl trinitrate and lateral internal sphincterotomy for the treatment of patients with chronic anal fissure: long-term follow-up. Eur J Surg. 2002;168(7):418-21. [pmid: 12463433].
420 Mishra R, Thomas S, Maan MS, et al. Topical nitroglycerin versus lateral internal sphincterotomy for chronic anal fissure: prospective, randomized trial. ANZ J Surg. Dec. 2005;75(12):1032-5. [pmid: 16398803].
421 Oettle GJ. Glyceryl trinitrate vs. sphincterotomy for treatment of chronic fissure-in-ano: a randomized, controlled trial. Dis Colon Rectum. Nov. 1997;40(11):1318-20. [pmid: 9369106].
422 Richard CS, Gregoire R, Plewes EA, et al. Internal sphincterotomy is superior to topical nitroglycerin in the treatment of chronic anal fissure: results of a randomized, controlled trial by the Canadian Colorectal Surgical Trials Group. Dis Colon Rectum. Aug. 2000;43(8):1048-57. discussion 57–8. [pmid: 10950002].
423 Evans J, Luck A, Hewett P. Glyceryl trinitrate vs. lateral sphincterotomy for chronic anal fissure: prospective, randomized trial. Dis Colon Rectum. Jan. 2001;44(1):93-7. [pmid: 11805569].
424 Peeters KC, van de Velde CJ, Leer JW, et al. Late side effects of short-course preoperative radiotherapy combined with total mesorectal excision for rectal cancer: increased bowel dysfunction in irradiated patients—a Dutch colorectal cancer group study. J Clin Oncol. Sep 1. 2005;23(25):6199-206. [pmid: 16135487].
425 Dahlberg M, Glimelius B, Graf W, et al. Preoperative irradiation affects functional results after surgery for rectal cancer: results from a randomized study. Dis Colon Rectum. May. 1998;41(5):543-9. discussion 9–51. [pmid: 9593234].
426 Allgayer H, Dietrich CF, Rohde W, et al. Prospective comparison of short- and long-term effects of pelvic floor exercise/biofeedback training in patients with fecal incontinence after surgery plus irradiation versus surgery alone for colorectal cancer: clinical, functional and endoscopic/endosonographic findings. Scand J Gastroenterol. Oct. 2005;40(10):1168-75. [pmid: 16165701].
427 Wong WD, Congliosi SM, Spencer MP, et al. The safety and efficacy of the artificial bowel sphincter for fecal incontinence: results from a multicenter cohort study. Dis Colon Rectum. Sep. 2002;45(9):1139-53. [pmid: 12352228].
428 Yoshioka K, Ogunbiyi OA, Keighley MR. A pilot study of total pelvic floor repair or gluteus maximus transposition for postobstetric neuropathic fecal incontinence. Dis Colon Rectum. Feb. 1999;42(2):252-7. [pmid: 10211504].
429 Wexner SD, Baeten C, Bailey R, et al. Long-term efficacy of dynamic graciloplasty for fecal incontinence. Dis Colon Rectum. Jun. 2002;45(6):809-18. [pmid: 12072635].
430 Baeten CG, Bailey HR, Bakka A, et al. Safety and efficacy of dynamic graciloplasty for fecal incontinence: report of a prospective, multicenter trial. Dynamic Graciloplasty Therapy Study Group. Dis Colon Rectum. Jun. 2000;43(6):743-51. [pmid: 10859072].
431 Reilly WT, Pemberton JH, Wolff BG, et al. Randomized prospective trial comparing ileal pouch-anal anastomosis performed by excising the anal mucosa to ileal pouch-anal anastomosis performed by preserving the anal mucosa. Ann Surg. Jun. 1997;225(6):666-76. discussion 76–7. [pmid: 9230807]. [pmcid: 1190866].
432 Johnston D, Williamson ME, Lewis WG, et al. Prospective controlled trial of duplicated (J) versus quadruplicated (W) pelvic ileal reservoirs in restorative proctocolectomy for ulcerative colitis. Gut. Aug. 1996;39(2):242-7. [pmid: 8991863]. [pmcid: 1383306].
433 Selvaggi F, Giuliani A, Gallo C, et al. Randomized, controlled trial to compare the J-pouch and W-pouch configurations for ulcerative colitis in the maturation period. Dis Colon Rectum. May. 2000;43(5):615-20. [pmid: 10826420].
434 Oresland T, Fasth S, Hulten L, et al. Does balloon dilatation and anal sphincter training improve ileoanal-pouch function?. Int J Colorectal Dis. Aug. 1988;3(3):153-7. [pmid: 3183476].
435 Porru D, Usai E. Standard and extramural ambulatory urodynamic investigation for the diagnosis of detrusor instability-correlated incontinence and micturition disorders. Neurourol Urodyn. 1994;13(3):237-42. [pmid: 7920680].
436 Ishiko O, Hirai K, Sumi T, et al. The urinary incontinence score in the diagnosis of female urinary incontinence. Int J Gynaecol Obstet. Feb. 2000;68(2):131-7. [pmid: 10717817].
437 Yalcin I, Versi E, Benson JT, et al. Validation of a clinical algorithm to diagnose stress urinary incontinence for large studies. J Urol. Jun. 2004;171(6 Pt 1):2321-5. [pmid: 15126813].
438 Diokno AC, Normolle DP, Brown MB, et al. Urodynamic tests for female geriatric urinary incontinence. Urology. Nov. 1990;36(5):431-9. [pmid: 2238302].
439 Ramsay IN, Hilton P, Rice N. The symptomatic characterization of patients with detrusor instability and those with genuine stress incontinence. International Urogynecology Journal. 1993;4:23-6.
440 De Muylder X, Claes H, Neven P, et al. Usefulness of urodynamic investigations in female incontinence. Eur J Obstet Gynecol Reprod Biol. May 13. 1992;44(3):205-8. [pmid: 1607060].
441 Lagro-Janssen AL, Debruyne FM, van Weel C. Value of the patient's case history in diagnosing urinary incontinence in general practice. Br J Urol. Jun. 1991;67(6):569-72. [pmid: 2070199].
442 Clarke B. The role of urodynamic assessment in the diagnosis of lower urinary tract disorders. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):196-9. [pmid: 9449295].
443 Sand PK, Hill RC, Ostergard DR. Incontinence history as a predictor of detrusor stability. Obstet Gynecol. Feb. 1988;71(2):257-60. [pmid: 3336562].
444 Kujansuu E, Kauppila A. Scored urological history and urethrocystometry in the differential diagnosis of female urinary incontinence. Ann Chir Gynaecol. 1982;71(4):197-202. [pmid: 6889831].
445 Niecestro RM, Wheeler JS Jr, Nanninga J, et al. Use of stresscath for diagnosing stress incontinence. Urology. Mar. 1992;39(3):266-9. [pmid: 1546422].
446 Sunshine TJ, Glowacki GA. Clinical correlation of urodynamic testing in patients with urinary incontinence. Journal of Gynecologic Surgery. 1989;5:93-8.
447 Sandvik H, Hunskaar S, Vanvik A, et al. Diagnostic classification of female urinary incontinence: an epidemiological survey corrected for validity. J Clin Epidemiol. Mar. 1995;48(3):339-43. [pmid: 7897455].
448 Bergman A, Bader K. Reliability of the patient's history in the diagnosis of urinary incontinence. Int J Gynaecol Obstet. Jul. 1990;32(3):255-9. [pmid: 1972118].
449 Weidner AC, Myers ER, Visco AG, et al. Which women with stress incontinence require urodynamic evaluation?. Am J Obstet Gynecol. Jan. 2001;184(2):20-7. [pmid: 11174474].
450 Cundiff GW, Harris RL, Coates KW, et al. Clinical predictors of urinary incontinence in women. Am J Obstet Gynecol. Aug. 1997;177(2):262-6. discussion 6–7. [pmid: 9290438].
451 Le Coutour X, Jung-Faerber S, Klein P, et al. Female urinary incontinence: comparative value of history and urodynamic investigations. Eur J Obstet Gynecol Reprod Biol. Dec. 1990;37(3):279-86. [pmid: 2227071].
452 FitzGerald MP, Brubaker L. Urinary incontinence symptom scores and urodynamic diagnoses. Neurourol Urodyn. 2002;21(1):30-5. [pmid: 11835421].
453 Korda A, Krieger M, Hunter P, et al. The value of clinical symptoms in the diagnosis of urinary incontinence in the female. Aust N Z J Obstet Gynaecol. May. 1987;27(2):149-51. [pmid: 3675441].
454 Ouslander J, Staskin D, Raz S, et al. Clinical versus urodynamic diagnosis in an incontinent geriatric female population. J Urol. Jan. 1987;137(1):68-71. [pmid: 3795368].
455 Diokno AC, Wells TJ, Brink CA. Urinary incontinence in elderly women: urodynamic evaluation. J Am Geriatr Soc. Oct. 1987;35(10):940-6. [pmid: 3655177].
456 Pelsang RE, Bonney WW. Voiding cystourethrography in female stress incontinence. AJR Am J Roentgenol. Mar. 1996;166(3):561-5. [pmid: 8623628].
457 Scotti RJ, Ostergard DR, Guillaume AA, et al. Predictive value of urethroscopy as compared to urodynamics in the diagnosis of genuine stress incontinence. J Reprod Med. Aug. 1990;35(8):772-6. [pmid: 2213738].
458 Grischke EM, Anton H, Stolz W, et al. Urodynamic assessment and lateral urethrocystography. A comparison of two diagnostic procedures for female urinary incontinence. Acta Obstet Gynecol Scand. 1991;70(3):225-9. [pmid: 1927300].
459 Bergman A, McKenzie C, Ballard CA, et al. Role of cystourethrography in the preoperative evaluation of stress urinary incontinence in women. J Reprod Med. Apr. 1988;33(4):372-6. [pmid: 3367339].
460 Rose DH, Eaton AC. Observations in micturating cystourethrography. J R Soc Med. Feb. 1983;76(2):121-5. [pmid: 6827511]. [pmcid: 1438678].
461 Digesu GA, Khullar V, Cardozo L, et al. The open bladder neck: a significant finding?. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):336-9. [pmid: 15580420].
462 Swift SE. The reliability of performing a screening cystometrogram using a fetal monitoring device for the detection of detrusor instability. Obstet Gynecol. May. 1997;89(5 Pt 1):708-12. [pmid: 9166306].
463 Ouslander J, Leach G, Abelson S, et al. Simple versus multichannel cystometry in the evaluation of bladder function in an incontinent geriatric population. J Urol. Dec. 1988;140(6):1482-6. [pmid: 3193520].
464 Resnick NM, Brandeis GH, Baumann MM, et al. Misdiagnosis of urinary incontinence in nursing home women: prevalence and a proposed solution. Neurourol Urodyn. 1996;15(6):599-613. discussion -8. [pmid: 8916113].
465 Scotti RJ, Myers DL. A comparison of the cough stress test and single-channel cystometry with multichannel urodynamic evaluation in genuine stress incontinence. Obstet Gynecol. Mar. 1993;81(3):430-3. [pmid: 8437800].
466 Bergman A, McCarthy TA, Ballard CA, et al. Role of the Q-tip test in evaluating stress urinary incontinence. J Reprod Med. Apr. 1987;32(4):273-5. [pmid: 3585870].
467 Montz FJ, Stanton SL. Q-Tip test in female urinary incontinence. Obstet Gynecol. Feb. 1986;67(2):258-60. [pmid: 3945436].
468 Thomakos N, Young RL, Daskalakis G. The Q-tip test correlation with urethroscopic findings in urinary stress incontinence. Int J Gynaecol Obstet. Dec. 2005;91(3):264-5. [pmid: 16157336].
469 Noblett K, Lane FL, Driskill CS. Does pelvic organ prolapse quantification exam predict urethral mobility in stages 0 and I prolapse?. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):268-71. [pmid: 15856131].
470 Dietz HP, Clarke B. Translabial color Doppler urodynamics. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(5):304-7. [pmid: 11715995].
471 Quinn MJ, Fanrsworth BA, Pollard WJ, et al. Vaginal ultrasound in the diagnosis of stress incontinence: a prospective comparison to urodynamic investigations. Neurourol Urodyn. 1989;8:8. 302–3.
472 Kuo HC, Chang SC, Hsu T. Application of transrectal sonography in the diagnosis and treatment of female stress urinary incontinence. Eur Urol. 1994;26(1):77-84. [pmid: 7925535].
473 Dietz HP, Wilson PD. Anatomical assessment of the bladder outlet and proximal urethra using ultrasound and videocystourethrography. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(6):365-9. [pmid: 9891957].
474 Chen GD, Su TH, Lin LY. Applicability of perineal sonography in anatomical evaluation of bladder neck in women with and without genuine stress incontinence. J Clin Ultrasound. May. 1997;25(4):189-94. [pmid: 9142618].
475 Bergman A, Ballard CA, Platt LD. Ultrasonic evaluation of urethrovesical junction in women with stress urinary incontinence. J Clin Ultrasound. Jun. 1988;16(5):295-300. [pmid: 3152386].
476 Kiilholma PJ, Makinen JI, Pitkanen YA, et al. Perineal ultrasound: an alternative for radiography for evaluating stress urinary incontinence in females. Ann Chir Gynaecol Suppl. 1994;208:43-5. [pmid: 8092770].
477 Huang WC, Yang JM. Bladder neck funneling on ultrasound cystourethrography in primary stress urinary incontinence: a sign associated with urethral hypermobility and intrinsic sphincter deficiency. Urology. May. 2003;61(5):936-41. [pmid: 12736011].
478 Peters TJ, Horrocks S, Stoddart H, et al. Factors associated with variations in older people's use of community-based continence services. Health Soc Care Community. Jan. 2004;12(1):53-62. [pmid: 14675365].
479 Moore AA, Siu AL. Screening for common problems in ambulatory elderly: clinical confirmation of a screening instrument. Am J Med. Apr. 1996;100(4):438-43. [pmid: 8610731].
480 Kirschner-Hermanns R, Scherr PA, Branch LG, et al. Accuracy of survey questions for geriatric urinary incontinence. J Urol. Jun. 1998;159(6):1903-8. [pmid: 9598484].
481 Resnick NM, Brandeis GH, Baumann MM, et al. Evaluating a national assessment strategy for urinary incontinence in nursing home residents: reliability of the minimum data set and validity of the resident assessment protocol. Neurourol Urodyn. 1996;15(6):583-98. [pmid: 8916112].
482 Deen KI, Kumar D, Williams JG, et al. Anal sphincter defects. Correlation between endoanal ultrasound and surgery. Ann Surg. Aug. 1993;218(2):201-5. [pmid: 8343001]. [pmcid: 1242931].
483 Abrams P, Cardozo L, Fall M, et al. The standardisation of terminology in lower urinary tract function: report from the standardisation sub-committee of the International Continence Society. Urology. Jan. 2003;61(1):37-49. [pmid: 12559262].
484 Rockwood TH, Church JM, Fleshman JW, et al. Fecal Incontinence Quality of Life Scale: quality of life instrument for patients with fecal incontinence. Dis Colon Rectum. Jan. 2000;43(1):9-16. discussion -7. [pmid: 10813117].
485 Barbalias G, Liatsikos E, Barbalias D. Use of slings made of indigenous and allogenic material (Goretex) in type III urinary incontinence and comparison between them. Eur Urol. 1997;31(4):394-400. [pmid: 9187896].
486 Colombo M, Maggioni A, Scalambrino S, et al. Surgery for genitourinary prolapse and stress incontinence: a randomized trial of posterior pubourethral ligament plication and Pereyra suspension. Am J Obstet Gynecol. Feb. 1997;176(2):337-43. [pmid: 9065178].
487 Bump RC, Hurt WG, Theofrastous JP, et al. Randomized prospective comparison of needle colposuspension versus endopelvic fascia plication for potential stress incontinence prophylaxis in women undergoing vaginal reconstruction for stage III or IV pelvic organ prolapse. The Continence Program for Women Research Group. Am J Obstet Gynecol. Aug. 1996;175(2):326-33. discussion 33–5. [pmid: 8765249].
488 Hilton P. A clinical and urodynamic study comparing the Stamey bladder neck suspension and suburethral sling procedures in the treatment of genuine stress incontinence. Br J Obstet Gynaecol. Feb. 1989;96(2):213-20. [pmid: 2930745].
489 Wilson LC, Gilling PJ, Williams A, et al. A randomised trial comparing holmium laser enucleation versus transurethral resection in the treatment of prostates larger than 40 grams: results at 2 years. Eur Urol. Sep. 2006;50(3):569-73. [pmid: 16704894].
490 Zullo MA, Plotti F, Calcagno M, et al. Vaginal estrogen therapy and overactive bladder symptoms in postmenopausal patients after a tension-free vaginal tape procedure: a randomized clinical trial. Menopause. Jul–Aug. 2005;12(4):421-7. [pmid: 16037757].
491 Laurikainen E, Valpas A, Kivela A, et al. Retropubic compared with transobturator tape placement in treatment of urinary incontinence: a randomized controlled trial. Obstet Gynecol. Jan. 2007;109(1):4-11. [pmid: 17197581].
492 Dean NM, Ellis G, Wilson PD, et al. Laparoscopic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev 2006; 3:CD002239.
493 Shaikh S, Ong EK, Glavind K, et al. Mechanical devices for urinary incontinence in women. Cochrane Database Syst Rev 2006; 3:CD001756.
494 Lapitan MC, Cody DJ, Grant AM. Open retropubic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev 2005; (3):CD002912.
495 Glazener CM, Lapitan MC. Urodynamic investigations for management of urinary incontinence in adults. Cochrane Database Syst Rev 2002; (3):CD003195.
496 Brown SR, Nelson RL. Surgery for faecal incontinence in adults. Cochrane Database Syst Rev 2007; (2):CD001757.
497 Norton C, Cody JD, Hosker G. Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults. Cochrane Database Syst Rev 2006; 3:CD002111.
498 Coggrave M, Wiesel PH, Norton C. Management of faecal incontinence and constipation in adults with central neurological diseases. Cochrane Database Syst Rev 2006; (2):CD002115.
499 Deutekom M, Dobben A. Plugs for containing faecal incontinence. Cochrane Database Syst Rev 2005; (3):CD005086.
500 Cheetham M, Brazzelli M, Norton C, et al. Drug treatment for faecal incontinence in adults. Cochrane Database Syst Rev 2003; (3):CD002116.
501 Byrne CM, Solomon MJ, Rex J, et al. Telephone vs. face-to-face biofeedback for fecal incontinence: comparison of two techniques in 239 patients. Dis Colon Rectum. Dec. 2005;48(12):2281-8. [pmid: 16258709].
502 Jorge JM, Wexner SD, Morgado PJ Jr, et al. Optimization of sphincter function after the ileoanal reservoir procedure. A prospective, randomized trial. Dis Colon Rectum. May. 1994;37(5):419-23. [pmid: 8181400].
503 Carapeti EA, Kamm MA, Nicholls RJ, et al. Randomized, controlled trial of topical phenylephrine for fecal incontinence in patients after ileoanal pouch construction. Dis Colon Rectum. Aug. 2000;43(8):1059-63. [pmid: 10950003].
504 Woods SP, Childers M, Ellis RJ, et al. A battery approach for measuring neuropsychological change. Arch Clin Neuropsychol. Jan. 2006;21(1):83-9. [pmid: 16169705].
505 Sinaiko AR, Steinberger J, Moran A, et al. Relation of body mass index and insulin resistance to cardiovascular risk factors, inflammatory factors, and oxidative stress during adolescence. Circulation. Apr 19. 2005;111(15):1985-91. [pmid: 15837953].
506 Matharu G, Donaldson MM, McGrother CW, et al. Relationship between urinary symptoms reported in a postal questionnaire and urodynamic diagnosis. Neurourol Urodyn. 2005;24(2):100-5. [pmid: 15605372].
507 Yalcin I, Bump RC. Validation of two global impression questionnaires for incontinence. Am J Obstet Gynecol. Jul. 2003;189(1):98-101. [pmid: 12861145].
508 Edwards NI, Jones D. The prevalence of faecal incontinence in older people living at home. Age Ageing. Nov. 2001;30(6):503-7. [pmid: 11742780].
509 Harari D, Norton C, Lockwood L, et al. Treatment of constipation and fecal incontinence in stroke patients: randomized controlled trial. Stroke. Nov. 2004;35(11):2549-55. [pmid: 15486330].
510 Moore KH, O'Sullivan RJ, Simons A, et al. Randomised controlled trial of nurse continence advisor therapy compared with standard urogynaecology regimen for conservative incontinence treatment: efficacy, costs and two year follow up. Bjog. Jul. 2003;110(7):649-57. [pmid: 12842055].
511 Ilnyckyj A, Fachnie E, Tougas G. A randomized-controlled trial comparing an educational intervention alone vs education and biofeedback in the management of faecal incontinence in women. Neurogastroenterol Motil. Feb. 2005;17(1):58-63. [pmid: 15670265].
512 Yamanishi T, Sakakibara R, Uchiyama T, et al. Comparative study of the effects of magnetic versus electrical stimulation on inhibition of detrusor overactivity. Urology. Nov 1. 2000;56(5):777-81. [pmid: 11068300].
513 Goldstein SR, Nanavati N. Adverse events that are associated with the selective estrogen receptor modulator levormeloxifene in an aborted phase III osteoporosis treatment study. Am J Obstet Gynecol. Sep. 2002;187(3):521-7. [pmid: 12237621].
514 Stamp G, Kruzins G, Crowther C. Perineal massage in labour and prevention of perineal trauma: randomised controlled trial. Bmj. May 26. 2001;322(7297):1277-80. [pmid: 11375230]. [pmcid: 31922].
515 Rockwood TH, Church JM, Fleshman JW, et al. Patient and surgeon ranking of the severity of symptoms associated with fecal incontinence: the fecal incontinence severity index. Dis Colon Rectum. Dec. 1999;42(12):1525-32. [pmid: 10613469].
516 Carls C. The prevalence of stress urinary incontinence in high school and college-age female athletes in the midwest: implications for education and prevention. Urol Nurs 2007 Feb; 27(1):21–4, 39.
517 Morrison A, Levy R. Fraction of nursing home admissions attributable to urinary incontinence. Value Health. Jul–Aug. 2006;9(4):272-4. [pmid: 16903997].
518 Pretlove SJ, Radley S, Toozs-Hobson PM, et al. Prevalence of anal incontinence according to age and gender: a systematic review and meta-regression analysis. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):407-17. [pmid: 16572280].
519 Peet SM, Castleden CM, McGrother CW. Prevalence of urinary and faecal incontinence in hospitals and residential and nursing homes for older people. Bmj. Oct 21. 1995;311(7012):1063-4. [pmid: 7580664]. [pmcid: 2551367].
520 Black D. Faecal incontinence. Age Ageing. May. 2007;36(3):239-40. [pmid: 17379606].
521 Cohen SJ, Robinson D, Dugan E, et al. Communication between older adults and their physicians about urinary incontinence. J Gerontol A Biol Sci Med Sci. Jan. 1999;54(1):M34-7. [pmid: 10026660].
522 Terra MP. Faecal incontinence: diagnosis and treatment. S.l.: s.n.; 2006.
523 Putta S, Andreyev HJ. Faecal incontinence: A late side-effect of pelvic radiotherapy. Clin Oncol (R Coll Radiol). Sep. 2005;17(6):469-77. [pmid: 16149292].
524 Ho YH, Muller R, Veitch C, et al. Faecal incontinence: an unrecognised epidemic in rural North Queensland? Results of a hospital-based outpatient study. Aust J Rural Health. Feb. 2005;13(1):28-34. [pmid: 15720312].
525 Thomas LH, Barrett J, Cross S, et al. Prevention and treatment of urinary incontinence after stroke in adults. Cochrane Database Syst Rev 2005; (3):CD004462.
526 Roe B, Williams K, Palmer M. Bladder training for urinary incontinence in adults. Cochrane Database Syst Rev 2000; (2):CD001308.
527 Pickard R, Reaper J, Wyness L, et al. Periurethral injection therapy for urinary incontinence in women. Cochrane Database Syst Rev 2003; (2):CD003881.
528 Ostaszkiewicz J, Johnston L, Roe B. Timed voiding for the management of urinary incontinence in adults. Cochrane Database Syst Rev 2004; (1):CD002802.
529 Ostaszkiewicz J, Johnston L, Roe B. Habit retraining for the management of urinary incontinence in adults. Cochrane Database Syst Rev 2004; (2):CD002801.
530 Moore KN, Cody DJ, Glazener CM. Conservative management for post prostatectomy urinary incontinence. Cochrane Database Syst Rev 2001; (2):CD001843.
531 Moore KN, Cody DJ, Glazener CM. Conservative management of post prostatectomy incontinence. Cochrane Database Syst Rev 2000; (2):CD001843.
532 Moehrer B, Hextall A, Jackson S. Oestrogens for urinary incontinence in women. Cochrane Database Syst Rev 2003; (2):CD001405.
533 Moehrer B, Ellis G, Carey M, et al. Laparoscopic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev 2002; (1):CD002239.
534 Maher C, Baessler K, Glazener CM, et al. Surgical management of pelvic organ prolapse in women. Cochrane Database Syst Rev 2004; (4):CD004014.
535 Lapitan MC, Cody DJ, Grant AM. Open retropubic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev 2003; (1):CD002912.
536 Hunter KF, Moore KN, Cody DJ, et al. Conservative management for postprostatectomy urinary incontinence. Cochrane Database Syst Rev 2004; (2):CD001843.
537 Herbison P, Plevnik S, Mantle J. Weighted vaginal cones for urinary incontinence. Cochrane Database Syst Rev 2002; (1):CD002114.
538 Herbison P, Plevnik S, Mantle J. Weighted vaginal cones for urinary incontinence. Cochrane Database Syst Rev 2000; (2):CD002114.
539 Hay-Smith EJ, Dumoulin C. Pelvic floor muscle training versus no treatment, or inactive control treatments, for urinary incontinence in women. Cochrane Database Syst Rev 2006; (1):CD005654.
540 Hay-Smith EJ, Bo Berghmans LC, Hendriks HJ, et al. Pelvic floor muscle training for urinary incontinence in women. Cochrane Database Syst Rev 2001; (1):CD001407.
541 Glazener CM, Cooper K. Bladder neck needle suspension for urinary incontinence in women. Cochrane Database Syst Rev 2004; (2):CD003636.
542 Glazener CM, Cooper K. Bladder neck needle suspension for urinary incontinence in women. Cochrane Database Syst Rev 2002; (2):CD003636.
543 Glazener CM, Cooper K. Anterior vaginal repair for urinary incontinence in women. Cochrane Database Syst Rev 2001; (1):CD001755.
544 Glazener CM, Cooper K. Anterior vaginal repair for urinary incontinence in women. Cochrane Database Syst Rev 2000; (3):CD001755.
545 Eustice S, Roe B, Paterson J. Prompted voiding for the management of urinary incontinence in adults. Cochrane Database Syst Rev 2000; (2):CD002113.
546 Bezerra CA, Bruschini H, Cody DJ. Traditional suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev 2005; (3):CD001754.
547 Bezerra CA, Bruschini H. Suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev 2001; (3):CD001754.
548 Bezerra CA, Bruschini H. Suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev 2000; (3):CD001754.
549 Norton C, Hosker G, Brazzelli M. Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults. Cochrane Database Syst Rev 2000; (2):CD002111.
550 Lethaby A, Ivanova V, Johnson NP. Total versus subtotal hysterectomy for benign gynaecological conditions. Cochrane Database Syst Rev 2006; (2):CD004993.
551 Hosker G, Norton C, Brazzelli M. Electrical stimulation for faecal incontinence in adults. Cochrane Database Syst Rev 2000; (2):CD001310.
552 Hay-Smith J, Herbison P, Morkved S. Physical therapies for prevention of urinary and faecal incontinence in adults. Cochrane Database Syst Rev 2002; (2):CD003191.
553 Guenaga KF, Matos D, Castro AA, et al. Mechanical bowel preparation for elective colorectal surgery. Cochrane Database Syst Rev 2005; (1):CD001544.
554 Guenaga KF, Matos D, Castro AA, et al. Mechanical bowel preparation for elective colorectal surgery. Cochrane Database Syst Rev 2003; (2):CD001544.
555 Fernando R, Sultan AH, Kettle C, et al. Methods of repair for obstetric anal sphincter injury. Cochrane Database Syst Rev 2006; 3:CD002866.
556 Bachoo P, Brazzelli M, Grant A. Surgery for faecal incontinence in adults. Cochrane Database Syst Rev 2000; (2):CD001757.
557 Bachoo P, Brazzelli M, Grant A. Surgery for complete rectal prolapse in adults. Cochrane Database Syst Rev 2000; (2):CD001758.
558 Anger JT, Saigal CS, Madison R, et al. Increasing costs of urinary incontinence among female Medicare beneficiaries. J Urol. Jul. 2006;176(1):247-51. discussion 51. [pmid: 16753411].
559 Hu TW, Wagner TH, Bentkover JD, et al. Costs of urinary incontinence and overactive bladder in the United States: a comparative study. Urology. Mar. 2004;63(3):461-5. [pmid: 15028438].
560 Higgins J, Green S. The Cochrane Collaboration. The Cochrane handbook for systematic reviews of interventions. John Wiley & Sons, Ltd. Cochrane Collaboration. Available at: http://www.cochrane.org/resources/handbook/handbook.pdf, 2006.
561 United States Agency for Healthcare Research and Quality. Systems to Rate the Strength of Scientific Evidence. Rockville, MD: University of California SF-SE-BPC; 2002.
562 Hamer S, Collinson G. Achieving Evidence-based Practice: A Handbook for Practitioners. Edinburgh: B. Tindall; 1999.
563 Dawson B, Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). 3rd ed. New York: Lange Medical Books-McGraw-Hill; 2004.
564 Kahn HA, Sempos CT. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). USA: Oxford University Press; 1989.
565 Al-Marzouki S, Evans S, Marshall T, et al. Are these data real? Statistical methods for the detection of data fabrication in clinical trials. BMJ. Jul 30. 2005;331(7511):267-70. [pmid: 16052019]. [pmcid: 1181267].
566 Buyse M, George SL, Evans S, et al. The role of biostatistics in the prevention, detection and treatment of fraud in clinical trials. Statistics in Medicine. 1999;18(24):3435-51. [pmid: 10611617].
567 Moher D, Cook DJ, Eastwood S, et al. Improving the quality of reports of meta-analyses of randomised controlled trials: the QUOROM statement. Quality of Reporting of Meta-analyses. Lancet. Nov 27. 1999;354(9193):1896-900. [pmid: 10584742].
568 Aschengrau A, Seage GR. Essentials of Epidemiology in Public Health. Sudbury, Mass: Jones and Bartlett; 2003.
569 Vist GE, Hagen KB, Devereaux PJ, et al. Outcomes of patients who participate in randomised controlled trials compared to similar patients receiving similar interventions who do not participate. Cochrane Database Syst Rev 2007; (2):MR000009.
570 Egger M, Smith GD. Bias in location and selection of studies. BMJ. Jan 3. 1998;316(7124):61-6. [pmid: 9451274].
571 Dickersin K, Min YI. NIH clinical trials and publication bias. Online J Curr Clin Trials 1993 Apr 28; Doc No 50:[4967 words; 53 paragraphs].
572 Thornton A, Lee P. Publication bias in meta-analysis: its causes and consequences. J Clin Epidemiol. Feb. 2000;53(2):207-16. [pmid: 10729693].
573 Whitehead A. Meta-analysis of controlled clinical trials. Chichester; New York: John Wiley & Sons; 2002.
574 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
575 Viechtbauer W. Confidence intervals for the amount of heterogeneity in meta-analysis. Stat Med 2006 Feb 6.
576 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
577 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London: NetLibrary, Inc. BMJ Books; 2001.
578 Nuotio M, Jylha M, Luukkaala T, et al. Urgency, urge incontinence and voiding symptoms in men and women aged 70 years and over. BJU Int. Mar. 2002;89(4):350-5. [pmid: 11872023].
579 Hunskaar S, Burgio KL, Clark A, et al. Epidemiology of urinary (UI) and faecal (FI) incontinence and pelvic organ prolapse (POP). In: Abrams P, Khoury S, Wein A, et al., eds. Incontinence, Volume I. Basics and Evaluation. Report from the Third International Consultation on Incontinence. Plymouth, UK: Health Communications Press; 2004; 257–312.
580 Buchsbaum GM, Duecy EE, Kerr LA, et al. Urinary incontinence in nulliparous women and their parous sisters. Obstet Gynecol. Dec. 2005;106(6):1253-8. [pmid: 16319249].
581 Dallosso HM, McGrother CW, Matthews RJ, et al. Nutrient composition of the diet and the development of overactive bladder: a longitudinal study in women. Neurourol Urodyn. 2004;23(3):204-10. [pmid: 15098215].
582 Nuotio M, Tammela TL, Luukkaala T, et al. Urgency and urge incontinence in an older population: ten-year changes and their association with mortality. Aging Clin Exp Res. Oct. 2002;14(5):412-9. [pmid: 12602577].
583 Malmsten UG, Milsom I, Molander U, et al. Urinary incontinence and lower urinary tract symptoms: an epidemiological study of men aged 45 to 99 years. J Urol. Nov. 1997;158(5):1733-7. [pmid: 9334589].
584 Koskimaki J, Hakama M, Huhtala H, et al. Prevalence of lower urinary tract symptoms in Finnish men: a population-based study. Br J Urol. Mar. 1998;81(3):364-9. [pmid: 9523653].
585 Boyle P, Robertson C, Mazzetta C, et al. The prevalence of male urinary incontinence in four centres: the UREPIK study. BJU Int. Dec. 2003;92(9):943-7. [pmid: 14632852].
586 Haltbakk J, Hanestad BR, Hunskaar S. Diversity of urinary symptoms in patients tentatively diagnosed with benign prostatic hyperplasia referred to a urologic clinic in Norway. Scand J Urol Nephrol. 2004;38(6):454-61. [pmid: 15841777].
587 Schulman C, Claes H, Matthijs J. Urinary incontinence in Belgium: a population-based epidemiological survey. Eur Urol. 1997;32(3):315-20. [pmid: 9358220].
588 Lewinshtein DJ, Perrotte P, Lebeau T, et al. Normal urinary and sexual function in men without evidence of prostate cancer from Montreal, Canada. BJU Int. Jun. 2006;97(6):1273-7. [pmid: 16686725].
589 Diokno AC, Estanol MV, Ibrahim IA, et al. Prevalence of urinary incontinence in community dwelling men: a cross sectional nationwide epidemiological survey. Int Urol Nephrol. 2007;39(1):129-36. [pmid: 17086446].
590 Roberts RO, Jacobsen SJ, Rhodes T, et al. Urinary incontinence in a community-based cohort: prevalence and healthcare-seeking. J Am Geriatr Soc. Apr. 1998;46(4):467-72. [pmid: 9560070].
591 Stothers L, Thom D, Calhoun E. Urologic diseases in America project: urinary incontinence in males—demographics and economic burden. J Urol. Apr. 2005;173(4):1302-8. [pmid: 15758786].
592 Miles TP, Palmer RF, Espino DV, et al. New-onset incontinence and markers of frailty: data from the Hispanic Established Populations for Epidemiologic Studies of the Elderly. J Gerontol A Biol Sci Med Sci. Jan. 2001;56(1):M19-24. [pmid: 11193227].
593 Palmer MH, Fitzgerald S, Berry SJ, et al. Urinary incontinence in working women: an exploratory study. Women Health. 1999;29(3):67-82. [pmid: 10466511].
594 Roe B, Doll H. Lifestyle factors and continence status: Comparison of self-report data from a postal survey in England. J WOCN. 1999;26:312-9.
595 Langa KM, Fultz NH, Saint S, et al. Informal caregiving time and costs for urinary incontinence in older individuals in the United States. J Am Geriatr Soc. Apr. 2002;50(4):733-7. [pmid: 11982676].
596 Lewis CM, Schrader R, Many A, et al. Diabetes and urinary incontinence in 50- to 90-year-old women: a cross-sectional population-based study. Am J Obstet Gynecol. Dec. 2005;193(6):2154-8. [pmid: 16325633].
597 Altman D, Zetterstrom J, Schultz I, et al. Pelvic organ prolapse and urinary incontinence in women with surgically managed rectal prolapse: a population-based case-control study. Dis Colon Rectum. Jan. 2006;49(1):28-35. [pmid: 16273329].
598 Mozes B, Shmueli A. Underutilization of health services among patients with urinary symptoms: results of a population-based survey in Israel. Prostate. Dec 1. 1997;33(4):246-51. [pmid: 9397196].
599 Engstrom G, Walker-Engstrom ML, Loof L, et al. Prevalence of three lower urinary tract symptoms in men-a population-based study. Fam Pract. Feb. 2003;20(1):7-10. [pmid: 12509363].
600 Chiang L, Ouslander J, Schnelle J, et al. Dually incontinent nursing home residents: clinical characteristics and treatment differences. J Am Geriatr Soc. Jun. 2000;48(6):673-6. [pmid: 10855605].
601 Buchanan RJ, Choi M, Wang S, et al. Analyses of nursing home residents in hospice care using the minimum data set. Palliat Med. Nov. 2002;16(6):465-80. [pmid: 12465693].
602 Brocklehurst J, Dickinson E, Windsor J. Laxatives and faecal incontinence in long-term care. Elder Care. Aug–Sep. 1998;10(4):22-5. [pmid: 9855925].
603 Prosser S, Dobbs F. Case-finding incontinence in the over-75s. Br J Gen Pract. Aug. 1997;47(421):498-500. [pmid: 9302789]. [pmcid: 1313079].
604 Walter S, Hallbook O, Gotthard R, et al. A population-based study on bowel habits in a Swedish community: prevalence of faecal incontinence and constipation. Scand J Gastroenterol. Aug. 2002;37(8):911-6. [pmid: 12229965].
605 Enck P, Bielefeldt K, Rathmann W, et al. Epidemiology of faecal incontinence in selected patient groups. Int J Colorectal Dis. Aug. 1991;6(3):143-6. [pmid: 1744485].
606 Thomas TM, Egan M, Walgrove A, et al. The prevalence of faecal and double incontinence. Community Med. Aug. 1984;6(3):216-20. [pmid: 6478780].
607 Diokno AC, Brock BM, Herzog AR, et al. Medical correlates of urinary incontinence in the elderly. Urology. Aug. 1990;36(2):129-38. [pmid: 2385880].
608 O'Keefe EA, Talley NJ, Zinsmeister AR, et al. Bowel disorders impair functional status and quality of life in the elderly: a population-based study. J Gerontol A Biol Sci Med Sci. Jul. 1995;50(4):M184-9. [pmid: 7614239].
609 Verhagen TE, Lagro-Janssen AL. [Fecal incontinence in community-dwelling elderly: findings from a study of prevalence, consultation of physicians, psychosocial aspects and treatment]. Ned Tijdschr Geneeskd. Apr 14. 2001;145(15):741-4. [pmid: 11332258].
610 Drossman DA, Li Z, Andruzzi E, et al. U.S. householder survey of functional gastrointestinal disorders. Prevalence, sociodemography, and health impact. Dig Dis Sci. Sep. 1993;38(9):1569-80. [pmid: 8359066].
611 Perry S, Shaw C, McGrother C, et al. Prevalence of faecal incontinence in adults aged 40 years or more living in the community. Gut. Apr. 2002;50(4):480-4. [pmid: 11889066]. [pmcid: 1773171].
612 Roche B, Chautems R, Rakotoarimanana R, et al. [Epidemiology of anal incontinence]. Rev Med Suisse Romande. Feb. 2002;122(2):71-4. [pmid: 11977466].
613 Lopes MC, Teixeira MG, Jacob Filho W, et al. [Prevalence of anal incontinence in the elderly population: an epidemiological study of the elderly population served at the geriatric ambulatory service of the Hospital das Clinicas da Faculdade de Medicina da Universidade de Sao Paulo]. Rev Hosp Clin Fac Med Sao Paulo. Jan–Feb. 1997;52(1):1-12. [pmid: 9334464].
614 Griffiths AN, Makam A, Edwards GJ. Should we actively screen for urinary and anal incontinence in the general gynaecology outpatients setting?—A prospective observational study. J Obstet Gynaecol. Jul. 2006;26(5):442-4. [pmid: 16846873].
615 Gordon D, Groutz A, Goldman G, et al. Anal incontinence: prevalence among female patients attending a urogynecologic clinic. Neurourol Urodyn. 1999;18(3):199-204. [pmid: 10338440].
616 Kjolhede P, Hallbook O, Ryden G, et al. Anorectal manometry in women with urinary stress incontinence. Acta Obstet Gynecol Scand. Mar. 1997;76(3):266-70. [pmid: 9093143].
617 Hojberg KE, Hundborg HH, Ryhammer AM, et al. The impact of delivery on anorectal function in women with and women without anal incontinence—a prospective study. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):38-45. discussion. [pmid: 12601515].
618 Lam K, Chen, Lubowski. Talley Prevalence of faecal incontinence: obstetric and constipation-related risk factors; a population-based study. Colorectal Disease. 1999;1(4):197-203.
619 Alnaif B, Drutz HP. The prevalence of urinary and fecal incontinence in Canadian secondary school teenage girls: questionnaire study and review of the literature. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):134-7. discussion8. [pmid: 11374512].
620 Okonkwo JE, Obionu CN, Okonkwo CV, et al. Anal incontinence among Igbo (Nigerian) women. Int J Clin Pract. Apr. 2002;56(3):178-80. [pmid: 12018821].
621 Rizk DE, Hassan MY, Shaheen H, et al. The prevalence and determinants of health care-seeking behavior for fecal incontinence in multiparous United Arab Emirates females. Dis Colon Rectum. Dec. 2001;44(12):1850-6. [pmid: 11742174].
622 Nelson R, Norton N, Cautley E, et al. Community-based prevalence of anal incontinence. Jama. Aug 16. 1995;274(7):559-61. [pmid: 7629985].
623 Damon H, Guye O, Seigneurin A, et al. Prevalence of anal incontinence in adults and impact on quality-of-life. Gastroenterol Clin Biol. Jan. 2006;30(1):37-43. [pmid: 16514381].
624 Giebel GD, Lefering R, Troidl H, et al. Prevalence of fecal incontinence: what can be expected?. Int J Colorectal Dis. 1998;13(2):73-7. [pmid: 9638491].
625 Campbell AJ, Reinken J, McCosh L. Incontinence in the elderly: prevalence and prognosis. Age Ageing. Mar. 1985;14(2):65-70. [pmid: 4003185].
626 Bytzer P, Talley NJ, Leemon M, et al. Prevalence of gastrointestinal symptoms associated with diabetes mellitus: a population-based survey of 15,000 adults. Arch Intern Med. Sep 10. 2001;161(16):1989-96. [pmid: 11525701].
627 Lynch AC, Dobbs BR, Keating J, et al. The prevalence of faecal incontinence and constipation in a general New Zealand population; a postal survey. N Z Med J. Oct 26. 2001;114(1142):474-7. [pmid: 11760243].
628 Jackson SL, Weber AM, Hull TL, et al. Fecal incontinence in women with urinary incontinence and pelvic organ prolapse. Obstet Gynecol. Mar. 1997;89(3):423-7. [pmid: 9052598].
629 Kahn MA, Breitkopf CR, Valley MT, et al. Pelvic Organ Support Study (POSST) and bowel symptoms: straining at stool is associated with perineal and anterior vaginal descent in a general gynecologic population. Am J Obstet Gynecol. May. 2005;192(5):1516-22. [pmid: 15902151].
630 Rortveit G, Hunskaar S. Urinary incontinence and age at the first and last delivery: the Norwegian HUNT/EPINCONT study. Am J Obstet Gynecol. Aug. 2006;195(2):433-8. [pmid: 16890552].
631 Persson J, Wolner-Hanssen P, Rydhstroem H. Obstetric risk factors for stress urinary incontinence: a population-based study. Obstet Gynecol. Sep. 2000;96(3):440-5. [pmid: 10960639].
632 Ertunc D, Tok EC, Pata O, et al. Is stress urinary incontinence a familial condition?. Acta Obstet Gynecol Scand. Oct. 2004;83(10):912-6. [pmid: 15453885].
633 Hannestad YS, Lie RT, Rortveit G, et al. Familial risk of urinary incontinence in women: population based cross sectional study. Bmj. Oct 16. 2004;329(7471):889-91. [pmid: 15485965]. [pmcid: 523112].
634 Rohr G, Kragstrup J, Gaist D, et al. Genetic and environmental influences on urinary incontinence: a Danish population-based twin study of middle-aged and elderly women. Acta Obstet Gynecol Scand. Oct. 2004;83(10):978-82. [pmid: 15453898].
635 Mushkat Y, Bukovsky I, Langer R. Female urinary stress incontinence—does it have familial prevalence?. Am J Obstet Gynecol. Feb. 1996;174(2):617-9. [pmid: 8623794].
636 Eliasson K, Nordlander I, Larson B, et al. Influence of physical activity on urinary leakage in primiparous women. Scand J Med Sci Sports. Apr. 2005;15(2):87-94. [pmid: 15773862].
637 Fitzgerald MP, Thom DH, Wassel-Fyr C, et al. Childhood urinary symptoms predict adult overactive bladder symptoms. J Urol. Mar. 2006;175(3 Pt 1):989-93. [pmid: 16469599]. [pmcid: 1820589].
638 McLennan MT, Melick CF, Bent AE. Leak-point pressure: clinical application of values at two different volumes. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2000;11(3):136-41. [pmid: 11484740].
639 Finkelstein MM, Skelly J, Kaczorowski J, et al. Incontinence Quality of Life Instrument in a survey of primary care physicians. J Fam Pract. Nov. 2002;51(11):952. [pmid: 12485550].
640 Eliasson K, Nordlander I, Mattsson E, et al. Prevalence of urinary leakage in nulliparous women with respect to physical activity and micturition habits. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):149-53. [pmid: 15167991].
641 Diokno AC, Brown MB, Herzog AR. Relationship between use of diuretics and continence status in the elderly. Urology. Jul. 1991;38(1):39-42. [pmid: 1866856].
642 Mariappan P, Ballantyne Z, N'Dow JM, et al. Serotonin and noradrenaline reuptake inhibitors (SNRI) for stress urinary incontinence in adults. Cochrane Database Syst Rev 2005; (3):CD004742.
643 Van Kampen M, De Weerdt W, Van Poppel H, et al. Urinary incontinence following transurethral, transvesical and radical prostatectomy. Retrospective study of 489 patients. Acta Urol Belg. Dec. 1997;65(4):1-7.
644 Catalona WJ, Carvalhal GF, Mager DE, et al. Potency, continence and complication rates in 1,870 consecutive radical retropubic prostatectomies. J Urol. Aug. 1999;162(2):433-8. [pmid: 10411052].
645 Maral I, Ozkardes H, Peskircioglu L, et al. Prevalence of stress urinary incontinence in both sexes at or after age 15 years: a cross-sectional study. J Urol. Feb. 2001;165(2):408-12. [pmid: 11176384].
646 Lee AH, Somerford PJ, Yau KK. Factors influencing survival after stroke in Western Australia. Med J Aust. Sep 15. 2003;179(6):289-93. [pmid: 12964910].
647 Di Carlo A, Lamassa M, Pracucci G, et al. Stroke in the very old: clinical presentation and determinants of 3-month functional outcome: A European perspective. European BIOMED Study of Stroke Care Group. Stroke. Nov. 1999;30(11):2313-9. [pmid: 10548664].
648 Hankey GJ, Jamrozik K, Broadhurst RJ, et al. Five-year survival after first-ever stroke and related prognostic factors in the Perth Community Stroke Study. Stroke. Sep. 2000;31(9):2080-6. [pmid: 10978033].
649 Lawrence ES, Coshall C, Dundas R, et al. Estimates of the prevalence of acute stroke impairments and disability in a multiethnic population. Stroke. Jun. 2001;32(6):1279-84. [pmid: 11387487].
650 van Kuijk AA, van der Linde H, van Limbeek J. Urinary incontinence in stroke patients after admission to a postacute inpatient rehabilitation program. Arch Phys Med Rehabil. Oct. 2001;82(10):1407-11. [pmid: 11588745].
651 Patel M, Coshall C, Rudd AG, et al. Natural history and effects on 2-year outcomes of urinary incontinence after stroke. Stroke. Jan. 2001;32(1):122-7. [pmid: 11136926].
652 Patel M, Coshall C, Lawrence E, et al. Recovery from poststroke urinary incontinence: associated factors and impact on outcome. J Am Geriatr Soc. Sep. 2001;49(9):1229-33. [pmid: 11559384].
653 Tang WK, Chan SS, Chiu HF, et al. Frequency and determinants of poststroke dementia in Chinese. Stroke. Apr. 2004;35(4):930-5. [pmid: 14976325].
654 Buchanan RJ, Wang S, Huang C, et al. Profiles of nursing home residents with multiple sclerosis using the minimum data set. Mult Scler. Jun. 2001;7(3):189-200. [pmid: 11475444].
655 Saxer S, Halfens RJ, Muller M, et al. Risk factors for urinary incontinence in nursing home residents. Swiss Med Wkly. Aug 20. 2005;135(3334):495-502. [pmid: 16208588].
656 Paolucci S, Antonucci G, Grasso MG, et al. The role of unilateral spatial neglect in rehabilitation of right brain-damaged ischemic stroke patients: a matched comparison. Arch Phys Med Rehabil. Jun. 2001;82(6):743-9. [pmid: 11387577].
657 McKinnie V, Swift SE, Wang W, et al. The effect of pregnancy and mode of delivery on the prevalence of urinary and fecal incontinence. Am J Obstet Gynecol. Aug. 2005;193(2):512-7. discussion 7–8. [pmid: 16098879].
658 Chiarelli P, Murphy B, Cockburn J. Fecal incontinence after high-risk delivery. Obstet Gynecol. Dec. 2003;102(6):1299-305. [pmid: 14662218].
659 Longstreth GF. Bowel patterns and anxiety. Demographic factors. J Clin Gastroenterol. Sep. 1993;17(2):128-32. [pmid: 8409315].
660 Bliss DZ, Fischer LR, Savik K. Managing fecal incontinence: self-care practices of older adults. J Gerontol Nurs. Jul. 2005;31(7):35-44. [pmid: 16047958].
661 Endo JO, Chen S, Potter JF, et al. Vitamin B(12) deficiency and incontinence: is there an association?. J Gerontol A Biol Sci Med Sci. Sep. 2002;57(9):M583-7. [pmid: 12196495].
662 van Brummen HJ, Bruinse HW, van de Pol G, et al. Defecatory symptoms during and after the first pregnancy: prevalences and associated factors. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):224-30. [pmid: 16077997].
663 Sullivan SN, Wong C. Runners' diarrhea. Different patterns and associated factors. J Clin Gastroenterol. Mar. 1992;14(2):101-4. [pmid: 1556421].
664 Welsh FK, McFall M, Mitchell G, et al. Pre-operative short-course radiotherapy is associated with faecal incontinence after anterior resection. Colorectal Dis. Nov. 2003;5(6):563-8. [pmid: 14617241].
665 Kienle P, Abend F, Dueck M, et al. Influence of intraoperative and postoperative radiotherapy on functional outcome in patients undergoing standard and deep anterior resection for rectal cancer. Dis Colon Rectum. May. 2006;49(5):557-67. [pmid: 16550319].
666 Tanum G, Tveit K, Karlsen KO, et al. Chemotherapy and radiation therapy for anal carcinoma. Survival and late morbidity. Cancer. May 15. 1991;67(10):2462-6. [pmid: 2015547].
667 Norderval S, Nsubuga D, Bjelke C, et al. Anal incontinence after obstetric sphincter tears: incidence in a Norwegian county. Acta Obstet Gynecol Scand. Oct. 2004;83(10):989-94. [pmid: 15453900].
668 Otegbayo JA, Talabi OA, Akere A, et al. Gastrointestinal complications in stroke survivors. Trop Gastroenterol. Jul–Sep. 2006;27(3):127-30. [pmid: 17310556].
669 Sakakibara R, Shinotoh H, Uchiyama T, et al. Questionnaire-based assessment of pelvic organ dysfunction in Parkinson's disease. Auton Neurosci. Sep 17. 2001;92(12):76-85. [pmid: 11570707].
670 Hinds JP, Eidelman BH, Wald A. Prevalence of bowel dysfunction in multiple sclerosis. A population survey. Gastroenterology. Jun. 1990;98(6):1538-42. [pmid: 2338192].
671 Menter R, Weitzenkamp D, Cooper D, et al. Bowel management outcomes in individuals with long-term spinal cord injuries. Spinal Cord. Sep. 1997;35(9):608-12. [pmid: 9300968].
672 Gonzalez-Argente FX, Jain A, Nogueras JJ, et al. Prevalence and severity of urinary incontinence and pelvic genital prolapse in females with anal incontinence or rectal prolapse. Dis Colon Rectum. Jul. 2001;44(7):920-6. [pmid: 11496068].
673 Lohmuller JL, Pemberton JH, Dozois RR, et al. Pouchitis and extraintestinal manifestations of inflammatory bowel disease after ileal pouch-anal anastomosis. Ann Surg. May. 1990;211(5):622-7. discussion 7–9. [pmid: 2339922]. [pmcid: 1358238].
674 Korman HJ, Mulholland TL, Huang R. Preservation of fecal continence and bowel function after radical perineal and retropubic prostatectomy: a questionnaire-based outcomes study. Prostate Cancer Prostatic Dis. 2004;7(3):249-52. [pmid: 15249929].
675 O'Connell B, Baker L, Munro I. The nature and impact of incontinence in men who have undergone prostate surgery and implications for nursing practice. Contemp Nurse. Feb. 2007;24(1):65-78. [pmid: 17348784].
676 Kirschner-Hermanns R, Borchers H, Reineke T, et al. Fecal incontinence after radical perineal prostatectomy: a prospective study. Urology. Feb. 2005;65(2):337-42. [pmid: 15708049].
677 Potosky AL, Legler J, Albertsen PC, et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study. J Natl Cancer Inst. Oct 4. 2000;92(19):1582-92. [pmid: 11018094].
678 Potosky AL, Davis WW, Hoffman RM, et al. Five-year outcomes after prostatectomy or radiotherapy for prostate cancer: the prostate cancer outcomes study. J Natl Cancer Inst. Sep 15. 2004;96(18):1358-67. [pmid: 15367568].
679 Nichols CM, Ramakrishnan V, Gill EJ, et al. Anal incontinence in women with and those without pelvic floor disorders. Obstet Gynecol. Dec. 2005;106(6):1266-71. [pmid: 16319251].
680 Leroi AM, Weber J, Menard JF, et al. Prevalence of anal incontinence in 409 patients investigated for stress urinary incontinence. Neurourol Urodyn. 1999;18(6):579-90. [pmid: 10529706].
681 Nichols CM, Gill EJ, Nguyen T, et al. Anal sphincter injury in women with pelvic floor disorders. Obstet Gynecol. Oct. 2004;104(4):690-6. [pmid: 15458887].
682 Rose J, Schneider C, Scheidbach H, et al. Laparoscopic treatment of rectal prolapse: experience gained in a prospective multicenter study. Langenbecks Arch Surg. Jul. 2002;387(34):130-7. [pmid: 12172857].
683 Kjolhede P, Wahlstrom J, Wingren G. Pelvic floor dysfunction after Burch colposuspension—a comprehensive study. Part II. Acta Obstet Gynecol Scand. Sep. 2005;84(9):902-8. [pmid: 16097984].
684 Groutz A, Fait G, Lessing JB, et al. Incidence and obstetric risk factors of postpartum anal incontinence. Scand J Gastroenterol. Mar. 1999;34(3):315-8. [pmid: 10232879].
685 Sze EH. Anal incontinence among women with one versus two complete third-degree perineal lacerations. Int J Gynaecol Obstet. Sep. 2005;90(3):213-7. [pmid: 15970289].
686 Sze EH. Prevalence and severity of anal incontinence in women with and without additional vaginal deliveries after a fourth-degree perineal laceration. Dis Colon Rectum. Jan. 2005;48(1):66-9. [pmid: 15690659].
687 Parmentier H, Damon H, Henry L, et al. Frequency of anal incontinence and results of pelvic viscerography in 291 women with pelvic organ prolapse. Gastroenterol Clin Biol. Mar. 2004;28(3):226-30. [pmid: 15094671].
688 Bugg GJ, Hosker GL, Kiff ES. Routine symptom screening for postnatal urinary and anal incontinence in new mothers from a district. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):405-8. [pmid: 15891806].
689 Mazouni C, Bretelle F, Battar S, et al. Frequency of persistent anal symptoms after first instrumental delivery. Dis Colon Rectum. Jul. 2005;48(7):1432-6. [pmid: 15933796].
690 Nygaard IE, Rao SS, Dawson JD. Anal incontinence after anal sphincter disruption: a 30-year retrospective cohort study. Obstet Gynecol. Jun. 1997;89(6):896-901. [pmid: 9170461].
691 Sangalli MR, Floris L, Faltin D, et al. Anal incontinence in women with third or fourth degree perineal tears and subsequent vaginal deliveries. Aust N Z J Obstet Gynaecol. Aug. 2000;40(3):244-8. [pmid: 11065029].
692 Frudinger A, Halligan S, Spencer JA, et al. Influence of the subpubic arch angle on anal sphincter trauma and anal incontinence following childbirth. Bjog. Nov. 2002;109(11):1207-12. [pmid: 12452456].
693 Wagenius J, Laurin J. Clinical symptoms after anal sphincter rupture: a retrospective study. Acta Obstet Gynecol Scand. Mar. 2003;82(3):246-50. [pmid: 12694121].
694 Peschers UM, Sultan AH, Jundt K, et al. Urinary and anal incontinence after vacuum delivery. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2003;110(1):39-42. [pmid: 12932869].
695 Faltin DL, Otero M, Petignat P, et al. Women's health 18 years after rupture of the anal sphincter during childbirth: I. Fecal incontinence. Am J Obstet Gynecol. May. 2006;194(5):1255-9. [pmid: 16647908].
696 Faltin DL, Sangalli MR, Roche B, et al. Does a second delivery increase the risk of anal incontinence?. Bjog. Jul. 2001;108(7):684-8. [pmid: 11467691].
697 Signorello LB, Harlow BL, Chekos AK, et al. Midline episiotomy and anal incontinence: retrospective cohort study. Bmj. Jan 8. 2000;320(7227):86-90. [pmid: 10625261]. [pmcid: 27253].
698 Lal M, C HM, Callender R, et al. Does cesarean delivery prevent anal incontinence?. Obstet Gynecol. Feb. 2003;101(2):305-12. [pmid: 12576254].
699 Sultan AH, Kamm MA, Bartram CI, et al. Anal sphincter trauma during instrumental delivery. Int J Gynaecol Obstet. Dec. 1993;43(3):263-70. [pmid: 7907036].
700 Meyer S, Hohlfeld P, Achtari C, et al. Birth trauma: short and long term effects of forceps delivery compared with spontaneous delivery on various pelvic floor parameters. Bjog. Nov. 2000;107(11):1360-5. [pmid: 11117762].
701 Schraffordt Koops SE, Vervest HA, Oostvogel HJ. Anorectal symptoms after various modes of vaginal delivery. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):244-9. discussion 9. [pmid: 14530835].
702 Curless R, French J, Williams GV, et al. Comparison of gastrointestinal symptoms in colorectal carcinoma patients and community controls with respect to age. Gut. Sep. 1994;35(9):1267-70. [pmid: 7959235]. [pmcid: 1375705].
703 Zetterstrom JP, Lopez A, Anzen B, et al. Anal incontinence after vaginal delivery: a prospective study in primiparous women. Br J Obstet Gynaecol. Apr. 1999;106(4):324-30. [pmid: 10426238].
704 Pregazzi R, Sartore A, Bortoli P, et al. Immediate postpartum perineal examination as a predictor of puerperal pelvic floor dysfunction. Obstet Gynecol. Apr. 2002;99(4):581-4. [pmid: 12039115].
705 Sultan AH, Kamm MA, Hudson CN, et al. Anal-sphincter disruption during vaginal delivery. N Engl J Med. Dec 23. 1993;329(26):1905-11. [pmid: 8247054].
706 Richter HE, Fielding JR, Bradley CS, et al. Endoanal ultrasound findings and fecal incontinence symptoms in women with and without recognized anal sphincter tears. Obstet Gynecol. Dec. 2006;108(6):1394-401. [pmid: 17138772].
707 Liebling RE, Swingler R, Patel RR, et al. Pelvic floor morbidity up to one year after difficult instrumental delivery and cesarean section in the second stage of labor: a cohort study. Am J Obstet Gynecol. Jul. 2004;191(1):4-10. [pmid: 15295337].
708 Ryden MB, Snyder M, Gross CR, et al. Value-added outcomes: the use of advanced practice nurses in long-term care facilities. Gerontologist. Dec. 2000;40(6):654-62. [pmid: 11131082].
709 Hu TW, Igou JF, Kaltreider DL, et al. A clinical trial of a behavioral therapy to reduce urinary incontinence in nursing homes. Outcome and implications. JAMA. May 12. 1989;261(18):2656-62. [pmid: 2496240].
710 Hu TW, Kaltreider DL, Igou JF, et al. Cost effectiveness of training incontinent elderly in nursing homes: a randomized clinical trial. Health Serv Res. Aug. 1990;25(3):455-77. [pmid: 2116385]. [pmcid: 1065639].
711 Ouslander JG, Greendale GA, Uman G, et al. Effects of oral estrogen and progestin on the lower urinary tract among female nursing home residents. J Am Geriatr Soc. Jun. 2001;49(6):803-7. [pmid: 11454122].
712 Chadha Y, Mollison J, Howie F, et al. Guidelines in gynaecology: evaluation in menorrhagia and in urinary incontinence. BJOG. Apr. 2000;107(4):535-43. [pmid: 10759275].
713 Dowd T, Kolcaba K, Steiner R. Using cognitive strategies to enhance bladder control and comfort. Holist Nurs Pract. Jan. 2000;14(2):91-103. [pmid: 12119974].
714 Subak LL, Whitcomb E, Shen H, et al. Weight loss: a novel and effective treatment for urinary incontinence. J Urol. Jul. 2005;174(1):190-5. [pmid: 15947625]. [pmcid: 1557356].
715 Manonai J, Songchitsomboon S, Chanda K, et al. The effect of a soy-rich diet on urogenital atrophy: a randomized, cross-over trial. Maturitas. May 20. 2006;54(2):135-40. [pmid: 16297576].
716 Dowd TT, Campbell JM, Jones JA. Fluid intake and urinary incontinence in older community-dwelling women. J Community Health Nurs. 1996;13(3):179-86. [pmid: 8916607].
717 Swithinbank L, Hashim H, Abrams P. The effect of fluid intake on urinary symptoms in women. J Urol. Jul. 2005;174(1):187-9. [pmid: 15947624].
718 Tomlinson BU, Dougherty MC, Pendergast JF, et al. Dietary caffeine, fluid intake and urinary incontinence in older rural women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):22-8. [pmid: 10207763].
719 Bryant CM, Dowell CJ, Fairbrother G. Caffeine reduction education to improve urinary symptoms. Br J Nurs. Apr 25–May 8. 2002;11(8):560-5. [pmid: 11979209].
720 Bo K, Talseth T, Vinsnes A. Randomized controlled trial on the effect of pelvic floor muscle training on quality of life and sexual problems in genuine stress incontinent women. Acta Obstet Gynecol Scand. Jul. 2000;79(7):598-603. [pmid: 10929962].
721 Cammu H, Van Nylen M. Pelvic floor exercises versus vaginal weight cones in genuine stress incontinence. Eur J Obstet Gynecol Reprod Biol. Mar. 1998;77(1):89-93. [pmid: 9550207].
722 Miller JM, Ashton-Miller JA, DeLancey JO. A pelvic muscle precontraction can reduce cough-related urine loss in selected women with mild SUI. J Am Geriatr Soc. Jul. 1998;46(7):870-4. [pmid: 9670874].
723 Sherman RA, Davis GD, Wong MF. Behavioral treatment of exercise-induced urinary incontinence among female soldiers. Mil Med. Oct. 1997;162(10):690-4. [pmid: 9339085].
724 Burns PA, Pranikoff K, Nochajski T, et al. Treatment of stress incontinence with pelvic floor exercises and biofeedback. J Am Geriatr Soc. Mar. 1990;38(3):341-4. [pmid: 2179379].
725 Wells TJ, Brink CA, Diokno AC, et al. Pelvic muscle exercise for stress urinary incontinence in elderly women. J Am Geriatr Soc. Aug. 1991;39(8):785-91. [pmid: 2071809].
726 Aukee P, Immonen P, Penttinen J, et al. Increase in pelvic floor muscle activity after 12 weeks' training: a randomized prospective pilot study. Urology. Dec. 2002;60(6):1020-3. discussion 3–4. [pmid: 12475661].
727 Berghmans LC, Frederiks CM, de Bie RA, et al. Efficacy of biofeedback, when included with pelvic floor muscle exercise treatment, for genuine stress incontinence. Neurourol Urodyn. 1996;15(1):37-52. [pmid: 8696355].
728 Liebergall-Wischnitzer M, Hochner-Celnikier D, Lavy Y, et al. Paula method of circular muscle exercises for urinary stress incontinence—a clinical trial. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):345-51. [pmid: 15660184].
729 Sung MS, Choi YH, Back SH, et al. The effect of pelvic floor muscle exercises on genuine stress incontinence among Korean women—focusing on its effects on the quality of life. Yonsei Med J. Apr. 2000;41(2):237-51. [pmid: 10817026].
730 Arvonen T, Fianu-Jonasson A, Tyni-Lenne R. Effectiveness of two conservative modes of physical therapy in women with urinary stress incontinence. Neurourol Urodyn. 2001;20(5):591-9. [pmid: 11574936].
731 Borello-France DF, Zyczynski HM, Downey PA, et al. Effect of pelvic-floor muscle exercise position on continence and quality-of-life outcomes in women with stress urinary incontinence. Phys Ther. Jul. 2006;86(7):974-86. [pmid: 16813477].
732 McDowell BJ, Engberg S, Sereika S, et al. Effectiveness of behavioral therapy to treat incontinence in homebound older adults. J Am Geriatr Soc. Mar. 1999;47(3):309-18. [pmid: 10078893].
733 Engberg S, Sereika SM, McDowell BJ, et al. Effectiveness of prompted voiding in treating urinary incontinence in cognitively impaired homebound older adults. J Wound Ostomy Continence Nurs. Sep. 2002;29(5):252-65. [pmid: 12510471].
734 Paterson J, Pinnock CB, Marshall VR. Pelvic floor exercises as a treatment for post-micturition dribble. Br J Urol. Jun. 1997;79(6):892-7. [pmid: 9202555].
735 Spruijt J, Vierhout M, Verstraeten R, et al. Vaginal electrical stimulation of the pelvic floor: a randomized feasibility study in urinary incontinent elderly women. Acta Obstet Gynecol Scand. Nov. 2003;82(11):1043-8. [pmid: 14616279].
736 Lappin MS, Lawrie FW, Richards TL, et al. Effects of a pulsed electromagnetic therapy on multiple sclerosis fatigue and quality of life: a double-blind, placebo controlled trial. Altern Ther Health Med. Jul–Aug. 2003;9(4):38-48.
737 Amaro JL, Gameiro MO, Kawano PR, et al. Intravaginal electrical stimulation: a randomized, double-blind study on the treatment of mixed urinary incontinence. Acta Obstet Gynecol Scand. 2006;85(5):619-22. [pmid: 16752244].
738 Berghmans B, van Waalwijk van Doorn E, Nieman F, et al. Efficacy of physical therapeutic modalities in women with proven bladder overactivity. Eur Urol. Jun. 2002;41(6):581-7. [pmid: 12074773].
739 Amaro JL, Gameiro MO, Padovani CR. Effect of intravaginal electrical stimulation on pelvic floor muscle strength. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):355-8. [pmid: 15647885].
740 But I, Faganelj M, Sostaric A. Functional magnetic stimulation for mixed urinary incontinence. J Urol. May. 2005;173(5):1644-6. [pmid: 15821527].
741 Bo K, Talseth T. Change in urethral pressure during voluntary pelvic floor muscle contraction and vaginal electrical stimulation. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(1):3-6. discussion -7. [pmid: 9260089].
742 Barroso JC, Ramos JG, Martins-Costa S, et al. Transvaginal electrical stimulation in the treatment of urinary incontinence. BJU Int. Feb. 2004;93(3):319-23. [pmid: 14764129].
743 Scheepens WA, de Bie RA, Weil EH, et al. Unilateral versus bilateral sacral neuromodulation in patients with chronic voiding dysfunction. J Urol. Nov. 2002;168(5):2046-50. [pmid: 12394705].
744 Karademir K, Baykal K, Sen B, et al. A peripheric neuromodulation technique for curing detrusor overactivity: Stoller afferent neurostimulation. Scand J Urol Nephrol. 2005;39(3):230-3. [pmid: 16118096].
745 Bower WF, Moore KH, Adams RD, et al. A urodynamic study of surface neuromodulation versus sham in detrusor instability and sensory urgency. J Urol. Dec. 1998;160(6 Pt 1):2133-6. [pmid: 9817339].
746 Walsh IK, Thompson T, Loughridge WG, et al. Non-invasive antidromic neurostimulation: a simple effective method for improving bladder storage. Neurourol Urodyn. 2001;20(1):73-84. [pmid: 11135384].
747 Fujishiro T, Takahashi S, Enomoto H, et al. Magnetic stimulation of the sacral roots for the treatment of urinary frequency and urge incontinence: an investigational study and placebo controlled trial. J Urol. Sep. 2002;168(3):1036-9. [pmid: 12187217].
748 Emmons SL, Otto L. Acupuncture for overactive bladder: a randomized controlled trial. Obstet Gynecol. Jul. 2005;106(1):138-43. [pmid: 15994629].
749 Lightner D, Calvosa C, Andersen R, et al. A new injectable bulking agent for treatment of stress urinary incontinence: results of a multicenter, randomized, controlled, double-blind study of Durasphere. Urology. Jul. 2001;58(1):12-5. [pmid: 11445471].
750 Lee PE, Kung RC, Drutz HP. Periurethral autologous fat injection as treatment for female stress urinary incontinence: a randomized double-blind controlled trial. J Urol. Jan. 2001;165(1):153-8. [pmid: 11125386].
751 Appell RA, Juma S, Wells WG, et al. Transurethral radiofrequency energy collagen micro-remodeling for the treatment of female stress urinary incontinence. Neurourol Urodyn. 2006;25(4):331-6. [pmid: 16673379].
752 Klein MC, Kaczorowski J, Firoz T, et al. A comparison of urinary and sexual outcomes in women experiencing vaginal and Caesarean births. J Obstet Gynaecol Can. Apr. 2005;27(4):332-9. [pmid: 15937606].
753 Sleep J, Grant A. West Berkshire perineal management trial: three year follow up. Br Med J (Clin Res Ed). Sep 26. 1987;295(6601):749-51.
754 Thakar R, Ayers S, Clarkson P, et al. Outcomes after total versus subtotal abdominal hysterectomy. N Engl J Med. Oct 24. 2002;347(17):1318-25. [pmid: 12397189].
755 Learman LA, Summitt RL Jr, Varner RE, et al. A randomized comparison of total or supracervical hysterectomy: surgical complications and clinical outcomes. Obstet Gynecol. Sep. 2003;102(3):453-62. [pmid: 12962924].
756 Lalos O, Bjerle P. Bladder wall mechanics and micturition before and after subtotal and total hysterectomy. Eur J Obstet Gynecol Reprod Biol. Mar. 1986;21(3):143-50. [pmid: 3956833].
757 Schraffordt Koops SE, Bisseling TM, Heintz AP, et al. The effectiveness of tension-free vaginal tape (TVT) and quality of life measured in women with previous urogynecologic surgery: analysis from The Netherlands TVT database. Am J Obstet Gynecol. Aug. 2006;195(2):439-44. [pmid: 16635472].
758 Ward K, Hilton P. Prospective multicentre randomised trial of tension-free vaginal tape and colposuspension as primary treatment for stress incontinence. BMJ. Jul 13. 2002;325(7355):67. [pmid: 12114234]. [pmcid: 117136].
759 Valpas A, Kivela A, Penttinen J, et al. Tension-free vaginal tape and laparoscopic mesh colposuspension in the treatment of stress urinary incontinence: immediate outcome and complications—a randomized clinical trial. Acta Obstet Gynecol Scand. Jul. 2003;82(7):665-71. [pmid: 12790850].
760 Dietz HP, Barry C, Lim YN, et al. Two-dimensional and three-dimensional ultrasound imaging of suburethral slings. Ultrasound Obstet Gynecol. Aug. 2005;26(2):175-9. [pmid: 15988786].
761 Brubaker L, Cundiff GW, Fine P, et al. Abdominal sacrocolpopexy with Burch colposuspension to reduce urinary stress incontinence. N Engl J Med. Apr 13. 2006;354(15):1557-66. [pmid: 16611949].
762 Roovers JP, van der Vaart CH, van der Bom JG, et al. A randomised controlled trial comparing abdominal and vaginal prolapse surgery: effects on urogenital function. Bjog. Jan. 2004;111(1):50-6. [pmid: 14687052].
763 Jarvis SK, Hallam TK, Lujic S, et al. Peri-operative physiotherapy improves outcomes for women undergoing incontinence and or prolapse surgery: results of a randomised controlled trial. Aust N Z J Obstet Gynaecol. Aug. 2005;45(4):300-3. [pmid: 16029296].
764 Demirci F, Yucel O. Comparison of pubovaginal sling and burch colposuspension procedures in type I/II genuine stress incontinence. Arch Gynecol Obstet. Nov. 2001;265(4):190-4. [pmid: 11789743].
765 Paraiso MF, Walters MD, Karram MM, et al. Laparoscopic Burch colposuspension versus tension-free vaginal tape: a randomized trial. Obstet Gynecol. Dec. 2004;104(6):1249-58. [pmid: 15572485].
766 El-Barky E, El-Shazly A, El-Wahab OA, et al. Tension free vaginal tape versus Burch colposuspension for treatment of female stress urinary incontinence. Int Urol Nephrol. 2005;37(2):277-81. [pmid: 16142556].
767 Wang AC, Chen MC. Comparison of tension-free vaginal taping versus modified Burch colposuspension on urethral obstruction: a randomized controlled trial. Neurourol Urodyn. 2003;22(3):185-90. [pmid: 12707868].
768 Berglund AL, Lalos O. The pre- and postsurgical nursing of women with stress incontinence. J Adv Nurs. Mar. 1996;23(3):502-11. [pmid: 8655825].
769 Osman T. Stress incontinence surgery for patients presenting with mixed incontinence and a normal cystometrogram. BJU Int. Dec. 2003;92(9):964-8. [pmid: 14632856].
770 Persson J, Teleman P, Eten-Bergquist C, et al. Cost-analyzes based on a prospective, randomized study comparing laparoscopic colposuspension with a tension-free vaginal tape procedure. Acta Obstet Gynecol Scand. Nov. 2002;81(11):1066-73. [pmid: 12421176].
771 Kitchener HC, Dunn G, Lawton V, et al. Laparoscopic versus open colposuspension—results of a prospective randomised controlled trial. BJOG. Sep. 2006;113(9):1007-13. [pmid: 16956332].
772 German KA, Kynaston H, Weight S, et al. A prospective randomized trial comparing a modified needle suspension procedure with the vagina/obturator shelf procedure for genuine stress incontinence. Br J Urol. Aug. 1994;74(2):188-90. [pmid: 7921936].
773 Zullo F, Morelli M, Russo T, et al. Two techniques of laparoscopic retropubic urethropexy. J Am Assoc Gynecol Laparosc. May. 2002;9(2):178-81. [pmid: 11960044].
774 Bergman A, Elia G. Three surgical procedures for genuine stress incontinence: five-year follow-up of a prospective randomized study. Am J Obstet Gynecol. Jul. 1995;173(1):66-71. [pmid: 7631729].
775 Ankardal M, Milsom I, Stjerndahl JH, et al. A three-armed randomized trial comparing open Burch colposuspension using sutures with laparoscopic colposuspension using sutures and laparoscopic colposuspension using mesh and staples in women with stress urinary incontinence. Acta Obstet Gynecol Scand. Aug. 2005;84(8):773-9. [pmid: 16026404].
776 Ankardal M, Ekerydh A, Crafoord K, et al. A randomised trial comparing open Burch colposuspension using sutures with laparoscopic colposuspension using mesh and staples in women with stress urinary incontinence. Bjog. Sep. 2004;111(9):974-81. [pmid: 15327613].
777 Ross J. Two techniques of laparoscopic Burch repair for stress incontinence: a prospective, randomized study. J Am Assoc Gynecol Laparosc. May. 1996;3(3):351-7. [pmid: 9050655].
778 Klarskov P, Belving D, Bischoff N, et al. Pelvic floor exercise versus surgery for female urinary stress incontinence. Urol Int. 1986;41(2):129-32. [pmid: 3727190].
779 Carey MP, Goh JT, Rosamilia A, et al. Laparoscopic versus open Burch colposuspension: a randomised controlled trial. BJOG. Sep. 2006;113(9):999-1006. [pmid: 16956331].
780 Little DJ, Kuban DA, Levy LB, et al. Quality-of-life questionnaire results 2 and 3 years after radiotherapy for prostate cancer in a randomized dose-escalation study. Urology. Oct. 2003;62(4):707-13. [pmid: 14550448].
781 Srougi M, Paranhos M, Leite KM, et al. The influence of bladder neck mucosal eversion and early urinary extravasation on patient outcome after radical retropubic prostatectomy: a prospective controlled trial. BJU Int. Apr. 2005;95(6):757-60. [pmid: 15794777].
782 Van Cangh PJ, Richard F, Lorge F, et al. Adjuvant radiation therapy does not cause urinary incontinence after radical prostatectomy: results of a prospective randomized study. J Urol. Jan. 1998;159(1):164-6. [pmid: 9400462].
783 Srougi M, Nesrallah LJ, Kauffmann JR, et al. Urinary continence and pathological outcome after bladder neck preservation during radical retropubic prostatectomy: a randomized prospective trial. J Urol. Mar. 2001;165(3):815-8. [pmid: 11176476].
784 Ghaly M, Wallner K, Merrick G, et al. The effect of supplemental beam radiation on prostate brachytherapy-related morbidity: morbidity outcomes from two prospective randomized multicenter trials. Int J Radiat Oncol Biol Phys. Apr 1. 2003;55(5):1288-93. [pmid: 12654439].
785 Imamoglu MA, Tuygun C, Bakirtas H, et al. The comparison of artificial urinary sphincter implantation and endourethral macroplastique injection for the treatment of postprostatectomy incontinence. Eur Urol. Feb. 2005;47(2):209-13. [pmid: 15661416].
786 Deliveliotis C, Delis A, Papatsoris A, et al. Local steroid application during nerve-sparing radical retropubic prostatectomy. BJU Int. Sep. 2005;96(4):533-5. [pmid: 16104905].
787 Parsons JK, Marschke P, Maples P, et al. Effect of methylprednisolone on return of sexual function after nerve-sparing radical retropubic prostatectomy. Urology. Nov. 2004;64(5):987-90. [pmid: 15533491].
788 Peeters ST, Lebesque JV, Heemsbergen WD, et al. Localized volume effects for late rectal and anal toxicity after radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. Mar 15. 2006;64(4):1151-61. [pmid: 16414208].
789 Akakura K, Isaka S, Akimoto S, et al. Long-term results of a randomized trial for the treatment of Stages B2 and C prostate cancer: radical prostatectomy versus external beam radiation therapy with a common endocrine therapy in both modalities. Urology. Aug. 1999;54(2):313-8. [pmid: 10443731].
790 Fransson P, Damber JE, Tomic R, et al. Quality of life and symptoms in a randomized trial of radiotherapy versus deferred treatment of localized prostate carcinoma. Cancer. Dec 15. 2001;92(12):3111-9. [pmid: 11753990].
791 Wasson JH, Reda DJ, Bruskewitz RC, et al. A comparison of transurethral surgery with watchful waiting for moderate symptoms of benign prostatic hyperplasia. The Veterans Affairs Cooperative Study Group on Transurethral Resection of the Prostate. N Engl J Med. Jan 12. 1995;332(2):75-9. [pmid: 7527493].
792 Gupta NP, Doddamani D, Aron M, et al. Vapor resection: a good alternative to standard loop resection in the management of prostates >40 cc. J Endourol. Dec. 2002;16(10):767-71. [pmid: 12542882].
793 Gallucci M, Puppo P, Perachino M, et al. Transurethral electrovaporization of the prostate vs. transurethral resection. Results of a multicentric, randomized clinical study on 150 patients. Eur Urol. 1998;33(4):359-64. [pmid: 9612677].
794 Vardy MD, Lindsay R, Scotti RJ, et al. Short-term urogenital effects of raloxifene, tamoxifen, and estrogen. Am J Obstet Gynecol. Jul. 2003;189(1):81-8. [pmid: 12861143].
795 Warming L, Christoffersen C, Riis BJ, et al. Adverse effects of a SERM (Levormeloxifene). Safety parameters and bone mineral density 12 months after treatment withdrawal. Maturitas. Mar 28. 2003;44(3):189-99. [pmid: 12648882].
796 Vestergaard P, Hermann AP, Stilgren L, et al. Effects of 5 years of hormonal replacement therapy on menopausal symptoms and blood pressure-a randomised controlled study. Maturitas. Oct 20. 2003;46(2):123-32. [pmid: 14559383].
797 Kok AL, Burger CW, van de Weijer PH, et al. Micturition complaints in postmenopausal women treated with continuously combined hormone replacement therapy: a prospective study. Maturitas. Jan 4. 1999;31(2):143-9. [pmid: 10227008].
798 Long CY, Liu CM, Hsu SC, et al. A randomized comparative study of the effects of oral and topical estrogen therapy on the lower urinary tract of hysterectomized postmenopausal women. Fertil Steril. Jan. 2006;85(1):155-60. [pmid: 16412747].
799 Jackson S, James M, Abrams P. The effect of oestradiol on vaginal collagen metabolism in postmenopausal women with genuine stress incontinence. Bjog. Mar. 2002;109(3):339-44. [pmid: 11950190].
800 Fantl JA, Bump RC, Robinson D, et al. Efficacy of estrogen supplementation in the treatment of urinary incontinence. The Continence Program for Women Research Group. Obstet Gynecol. Nov. 1996;88(5):745-9. [pmid: 8885906].
801 Jackson S, Shepherd A, Brookes S, et al. The effect of oestrogen supplementation on post-menopausal urinary stress incontinence: a double-blind placebo-controlled trial. Br J Obstet Gynaecol. Jul. 1999;106(7):711-8. [pmid: 10428529].
802 Ahlstrom K, Sandahl B, Sjoberg B, et al. Effect of combined treatment with phenylpropanolamine and estriol, compared with estriol treatment alone, in postmenopausal women with stress urinary incontinence. Gynecol Obstet Invest. 1990;30(1):37-43. [pmid: 2227611].
803 Cardozo L, Rekers H, Tapp A, et al. Oestriol in the treatment of postmenopausal urgency: a multicentre study. Maturitas. Dec. 1993;18(1):47-53. [pmid: 8107615].
804 Kinn AC, Lindskog M. Estrogens and phenylpropanolamine in combination for stress urinary incontinence in postmenopausal women. Urology. Sep. 1988;32(3):273-80. [pmid: 3046105].
805 Wilson PD, Faragher B, Butler B, et al. Treatment with oral piperazine oestrone sulphate for genuine stress incontinence in postmenopausal women. Br J Obstet Gynaecol. Jun. 1987;94(6):568-74. [pmid: 3113475].
806 Waetjen LE, Brown JS, Modelska K, et al. Effect of raloxifene on urinary incontinence: a randomized controlled trial. Obstet Gynecol. Feb. 2004;103(2):261-6. [pmid: 14754693].
807 von Holst T, Salbach B. Efficacy and tolerability of a new 7-day transdermal estradiol patch versus placebo in hysterectomized women with postmenopausal complaints. Maturitas. Feb 15. 2000;34(2):143-53. [pmid: 10714909].
808 Waetjen LE, Brown JS, Vittinghoff E, et al. The effect of ultralow-dose transdermal estradiol on urinary incontinence in postmenopausal women. Obstet Gynecol. Nov. 2005;106(5 Pt 1):946-52. [pmid: 16260511]. [pmcid: 1557395].
809 Lose G, Englev E. Oestradiol-releasing vaginal ring versus oestriol vaginal pessaries in the treatment of bothersome lower urinary tract symptoms. Bjog. Aug. 2000;107(8):1029-34. [pmid: 10955437].
810 Chompootaweep S, Nunthapisud P, Trivijitsilp P, et al. The use of two estrogen preparations (a combined contraceptive pill versus conjugated estrogen cream) intravaginally to treat urogenital symptoms in postmenopausal Thai women: a comparative study. Clin Pharmacol Ther. Aug. 1998;64(2):204-10. [pmid: 9728901].
811 Blom W, Sommers DK. The effects of an estradiol transdermal therapeutic system, alone and in combination with naproxen, on urge incontinence in elderly women: a pilot study: Trials in special populations. Current therapeutic research. 1995;56(10):1100-4.
812 Nabi G, Cody JD, Ellis G, et al. Anticholinergic drugs versus placebo for overactive bladder syndrome in adults. Cochrane Database Syst Rev 2006; (4):CD003781.
813 Alhasso A, Glazener CM, Pickard R, et al. Adrenergic drugs for urinary incontinence in adults. Cochrane Database Syst Rev 2005; (3):CD001842.
814 Kaplan SA, Roehrborn CG, Rovner ES, et al. Tolterodine and tamsulosin for treatment of men with lower urinary tract symptoms and overactive bladder: a randomized controlled trial. Jama. Nov 15. 2006;296(19):2319-28. [pmid: 17105794].
815 Morkved S, Bo K, Fjortoft T. Effect of adding biofeedback to pelvic floor muscle training to treat urodynamic stress incontinence. Obstet Gynecol. Oct. 2002;100(4):730-9. [pmid: 12383542].
816 Ward KL, Hilton P. A prospective multicenter randomized trial of tension-free vaginal tape and colposuspension for primary urodynamic stress incontinence: two-year follow-up. Am J Obstet Gynecol. Feb. 2004;190(2):324-31. [pmid: 14981369].
817 Chassagne P, Jego A, Gloc P, et al. Does treatment of constipation improve faecal incontinence in institutionalized elderly patients?. Age Ageing. Mar. 2000;29(2):159-64. [pmid: 10791451].
818 Pager CK, Solomon MJ, Rex J, et al. Long-term outcomes of pelvic floor exercise and biofeedback treatment for patients with fecal incontinence. Dis Colon Rectum. Aug. 2002;45(8):997-1003. [pmid: 12195181].
819 Norton C, Gibbs A, Kamm MA. Randomized, controlled trial of anal electrical stimulation for fecal incontinence. Dis Colon Rectum. Feb. 2006;49(2):190-6. [pmid: 16362803].
820 Chang HS, Myung SJ, Yang SK, et al. Effect of electrical stimulation in constipated patients with impaired rectal sensation. Int J Colorectal Dis. Sep. 2003;18(5):433-8. [pmid: 12677456].
821 Mahony RT, Malone PA, Nalty J, et al. Randomized clinical trial of intra-anal electromyographic biofeedback physiotherapy with intra-anal electromyographic biofeedback augmented with electrical stimulation of the anal sphincter in the early treatment of postpartum fecal incontinence. Am J Obstet Gynecol. Sep. 2004;191(3):885-90. [pmid: 15467559].
822 Ron Y, Avni Y, Lukovetski A, et al. Botulinum toxin type-A in therapy of patients with anismus. Dis Colon Rectum. Dec. 2001;44(12):1821-6. [pmid: 11742168].
823 Sun WM, Read NW, Verlinden M. Effects of loperamide oxide on gastrointestinal transit time and anorectal function in patients with chronic diarrhoea and faecal incontinence. Scand J Gastroenterol. Jan. 1997;32(1):34-8. [pmid: 9018764].
824 Carapeti EA, Kamm MA, Phillips RK. Randomized controlled trial of topical phenylephrine in the treatment of faecal incontinence. Br J Surg. Jan. 2000;87(1):38-42. [pmid: 10606908].
825 Nessim A, Wexner SD, Agachan F, et al. Is bowel confinement necessary after anorectal reconstructive surgery? A prospective, randomized, surgeon-blinded trial. Dis Colon Rectum. Jan. 1999;42(1):16-23. [pmid: 10211515].
826 Iswariah H, Stephens J, Rieger N, et al. Randomized prospective controlled trial of lateral internal sphincterotomy versus injection of botulinum toxin for the treatment of idiopathic fissure in ano. ANZ J Surg. Jul. 2005;75(7):553-5. [pmid: 15972045].
827 Brisinda G, Maria G, Bentivoglio AR, et al. A comparison of injections of botulinum toxin and topical nitroglycerin ointment for the treatment of chronic anal fissure. N Engl J Med. Jul 8. 1999;341(2):65-9. [pmid: 10395629].
828 Fitzpatrick M, Behan M, O'Connell PR, et al. A randomized clinical trial comparing primary overlap with approximation repair of third-degree obstetric tears. Am J Obstet Gynecol. Nov. 2000;183(5):1220-4. [pmid: 11084569].
829 Deen KI, Oya M, Ortiz J, et al. Randomized trial comparing three forms of pelvic floor repair for neuropathic faecal incontinence. Br J Surg. Jun. 1993;80(6):794-8. [pmid: 8330179].
830 Davis KJ, Kumar D, Poloniecki J. Adjuvant biofeedback following anal sphincter repair: a randomized study. Aliment Pharmacol Ther. Sep 1. 2004;20(5):539-49. [pmid: 15339325].
831 Deen KI, Kumar D, Williams JG, et al. Randomized trial of internal anal sphincter plication with pelvic floor repair for neuropathic fecal incontinence. Dis Colon Rectum. Jan. 1995;38(1):14-8. [pmid: 7813338].
832 Christensen P, Bazzocchi G, Coggrave M, et al. A randomized, controlled trial of transanal irrigation versus conservative bowel management in spinal cord-injured patients. Gastroenterology. Sep. 2006;131(3):738-47. [pmid: 16952543].
833 Wiley M, Day P, Rieger N, et al. Open vs. closed lateral internal sphincterotomy for idiopathic fissure-in-ano: a prospective, randomized, controlled trial. Dis Colon Rectum. Jun. 2004;47(6):847-52. [pmid: 15129311].
834 Parellada C. Randomized, prospective trial comparing 0.2 percent isosorbide dinitrate ointment with sphincterotomy in treatment of chronic anal fissure: a two-year follow-up. Dis Colon Rectum. Apr. 2004;47(4):437-43. [pmid: 14994114].
835 Arroyo Sebastian A, Perez Vicente F, Miranda Tauler E, et al. Surgical (close lateral internal sphincterotomy) versus chemical (botulinum toxin) sphincterotomy as treatment of chronic anal fissure. Med Clin (Barc). Apr 23. 2005;124(15):573-5. [pmid: 15860170].
836 Zbar AP, Ramesh J, Beer-Gabel M, et al. Conventional cutting vs. internal anal sphincter-preserving seton for high trans-sphincteric fistula: a prospective randomized manometric and clinical trial. Tech Coloproctol. Jul. 2003;7(2):89-94. [pmid: 14605927].
837 Osterberg A, Edebol Eeg-Olofsson K, Hallden M, et al. Randomized clinical trial comparing conservative and surgical treatment of neurogenic faecal incontinence. Br J Surg. Sep. 2004;91(9):1131-7. [pmid: 15449263].
838 Tjandra JJ, Lim JF, Hiscock R, et al. Injectable silicone biomaterial for fecal incontinence caused by internal anal sphincter dysfunction is effective. Dis Colon Rectum. Dec. 2004;47(12):2138-46. [pmid: 15657666].
839 O'Brien PE, Dixon JB, Skinner S, et al. A prospective, randomized, controlled clinical trial of placement of the artificial bowel sphincter (Acticon Neosphincter) for the control of fecal incontinence. Dis Colon Rectum. Nov. 2004;47(11):1852-60. [pmid: 15622577].
840 Seow-Choen F, Goh HS. Prospective randomized trial comparing J colonic pouch-anal anastomosis and straight coloanal reconstruction. Br J Surg. May. 1995;82(5):608-10. [pmid: 7613927].
841 Ho YH, Seow-Choen F, Tan M. Colonic J-pouch function at six months versus straight coloanal anastomosis at two years: randomized controlled trial. World J Surg. Jul. 2001;25(7):876-81. [pmid: 11572027].
842 Ho YH, Yu S, Ang ES, et al. Small colonic J-pouch improves colonic retention of liquids—randomized, controlled trial with scintigraphy. Dis Colon Rectum. Jan. 2002;45(1):76-82. [pmid: 11786768].
843 Soliani P, Carbognani P, Piccolo P, et al. Colostomy plug devices: a possible new approach to the problem of incontinence. Dis Colon Rectum. Oct. 1992;35(10):969-74. [pmid: 1395985].
844 Hallbook O, Pahlman L, Krog M, et al. Randomized comparison of straight and colonic J pouch anastomosis after low anterior resection. Ann Surg. Jul. 1996;224(1):58-65. [pmid: 8678619]. [pmcid: 1235247].
845 Ho YH, Brown S, Heah SM, et al. Comparison of J-pouch and coloplasty pouch for low rectal cancers: a randomized, controlled trial investigating functional results and comparative anastomotic leak rates. Ann Surg. Jul. 2002;236(1):49-55. [pmid: 12131085]. [pmcid: 1422548].
846 Machado M, Nygren J, Goldman S, et al. Functional and physiologic assessment of the colonic reservoir or side-to-end anastomosis after low anterior resection for rectal cancer: a two-year follow-up. Dis Colon Rectum. Jan. 2005;48(1):29-36. [pmid: 15690654].
847 Laurent A, Parc Y, McNamara D, et al. Colonic J-pouch-anal anastomosis for rectal cancer: a prospective, randomized study comparing handsewn vs. stapled anastomosis. Dis Colon Rectum. Apr. 2005;48(4):729-34. [pmid: 15719189].
848 Lazorthes F, Gamagami R, Chiotasso P, et al. Prospective, randomized study comparing clinical results between small and large colonic J-pouch following coloanal anastomosis. Dis Colon Rectum. Dec. 1997;40(12):1409-13. [pmid: 9407976].
849 Jiang JK, Yang SH, Lin JK. Transabdominal anastomosis after low anterior resection: A prospective, randomized, controlled trial comparing long-term results between side-to-end anastomosis and colonic J-pouch. Dis Colon Rectum. Nov. 2005;48(11):2100-8. discussion 8–10. [pmid: 16132480].
850 Furst A, Suttner S, Agha A, et al. Colonic J-pouch vs. coloplasty following resection of distal rectal cancer: early results of a prospective, randomized, pilot study. Dis Colon Rectum. Sep. 2003;46(9):1161-6. [pmid: 12972958].
851 Sailer M, Fuchs KH, Fein M, et al. Randomized clinical trial comparing quality of life after straight and pouch coloanal reconstruction. Br J Surg. Sep. 2002;89(9):1108-17. [pmid: 12190675].
852 Furst A, Burghofer K, Hutzel L, et al. Neorectal reservoir is not the functional principle of the colonic J-pouch: the volume of a short colonic J-pouch does not differ from a straight coloanal anastomosis. Dis Colon Rectum. May. 2002;45(5):660-7. [pmid: 12004217].
853 Hahnloser D, Pemberton JH, Wolff BG, et al. Results at up to 20 years after ileal pouch-anal anastomosis for chronic ulcerative colitis. Br J Surg. Mar. 2007;94(3):333-40. [pmid: 17225210].
854 McKee RF, Lauder JC, Poon FW, et al. A prospective randomized study of abdominal rectopexy with and without sigmoidectomy in rectal prolapse. Surg Gynecol Obstet. Feb. 1992;174(2):145-8. [pmid: 1734574].
855 Hasegawa H, Yoshioka K, Keighley MR. Randomized trial of fecal diversion for sphincter repair. Dis Colon Rectum. Jul. 2000;43(7):961-4. discussion 4–5. [pmid: 10910243].
856 Park JG, Lee MR, Lim SB, et al. Colonic J-pouch anal anastomosis after ultralow anterior resection with upper sphincter excision for low-lying rectal cancer. World J Gastroenterol. May 7. 2005;11(17):2570-3. [pmid: 15849813].
857 Lundby L, Krogh K, Jensen VJ, et al. Long-term anorectal dysfunction after postoperative radiotherapy for rectal cancer. Dis Colon Rectum. Jul. 2005;48(7):1343-9. discussion 9–52; author reply 52. [pmid: 15933797].
858 Umlauf MG, Mathis JA. Urinary incontinence among primiparous women. Urol Nurs. Dec. 1995;15(4):112-6. [pmid: 8701327].
859 Chiarelli P, Campbell E. Incontinence during pregnancy. Prevalence and opportunities for continence promotion. Aust N Z J Obstet Gynaecol. Feb. 1997;37(1):66-73. [pmid: 9075550].
860 Chiarelli P, Brown WJ. Leaking urine in Australian women: prevalence and associated conditions. Women Health. 1999;29(1):1-13. [pmid: 10427637].
861 Turan C, Zorlu CG, Ekin M, et al. Urinary incontinence in women of reproductive age. Gynecol Obstet Invest. 1996;41(2):132-4. [pmid: 8838975].
862 Rizk DE, Shaheen H, Thomas L, et al. The prevalence and determinants of health care-seeking behavior for urinary incontinence in United Arab Emirates women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):160-5. [pmid: 10430008].
863 Umlauf MG, Sherman SM. Symptoms of urinary incontinence among older community-dwelling men. J Wound Ostomy Continence Nurs. Nov. 1996;23(6):314-21. [pmid: 9043282].
864 Moorthy P, Lapitan MC, Quek PL, et al. Prevalence of overactive bladder in Asian men: an epidemiological survey. BJU Int. Mar. 2004;93(4):528-31. [pmid: 15008723].
865 Jitapunkul S, Khovidhunkit W. Urinary incontinence in Thai elderly living in Klong Toey slum. J Med Assoc Thai. Mar. 1998;81(3):160-8. [pmid: 9623006].
866 Avery KN, Bosch JL, Gotoh M, et al. Questionnaires to assess urinary and anal incontinence: review and recommendations. J Urol. Jan. 2007;177(1):39-49. [pmid: 17161997].
867 Versi E, Orrego G, Hardy E, et al. Evaluation of the home pad test in the investigation of female urinary incontinence. Br J Obstet Gynaecol. Feb. 1996;103(2):162-7. [pmid: 8616134].
868 Avery K, Donovan J, Peters TJ, et al. ICIQ: a brief and robust measure for evaluating the symptoms and impact of urinary incontinence. Neurourol Urodyn. 2004;23(4):322-30. [pmid: 15227649].
869 Brookes ST, Donovan JL, Wright M, et al. A scored form of the Bristol Female Lower Urinary Tract Symptoms questionnaire: data from a randomized controlled trial of surgery for women with stress incontinence. Am J Obstet Gynecol. Jul. 2004;191(1):73-82. [pmid: 15295345].
870 Kulseng-Hanssen S, Borstad E. The development of a questionnaire to measure the severity of symptoms and the quality of life before and after surgery for stress incontinence. BJOG. Nov. 2003;110(11):983-8. [pmid: 14592582].
871 Donovan JL, Peters TJ, Abrams P, et al. Scoring the short form ICSmaleSF questionnaire. International Continence Society. J Urol. Dec. 2000;164(6):1948-55. [pmid: 11061889].
872 Coyne K, Revicki D, Hunt T, et al. Psychometric validation of an overactive bladder symptom and health-related quality of life questionnaire: the OAB-q. Qual Life Res. Sep. 2002;11(6):563-74. [pmid: 12206577].
873 Shumaker SA, Wyman JF, Uebersax JS, et al. Health-related quality of life measures for women with urinary incontinence: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program in Women (CPW) Research Group. Qual Life Res. Oct. 1994;3(5):291-306. [pmid: 7841963].
874 Uebersax JS, Wyman JF, Shumaker SA, et al. Short forms to assess life quality and symptom distress for urinary incontinence in women: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program for Women Research Group. Neurourol Urodyn. 1995;14(2):131-9. [pmid: 7780440].
875 Sandvik H, Hunskaar S, Seim A, et al. Validation of a severity index in female urinary incontinence and its implementation in an epidemiological survey. J Epidemiol Community Health. Dec. 1993;47(6):497-9. [pmid: 8120507]. [pmcid: 1059866].
876 Jackson S, Donovan J, Brookes S, et al. The Bristol Female Lower Urinary Tract Symptoms questionnaire: development and psychometric testing. Br J Urol. Jun. 1996;77(6):805-12. [pmid: 8705212].
877 Donovan JL, Abrams P, Peters TJ, et al. The ICS-‘BPH’ Study: the psychometric validity and reliability of the ICSmale questionnaire. Br J Urol. Apr. 1996;77(4):554-62. [pmid: 8777617].
878 Hald T, Nordling J, Andersen JT, et al. A patient weighted symptom score system in the evaluation of uncomplicated benign prostatic hyperplasia. Scand J Urol Nephrol Suppl. 1991;138:59-62. [pmid: 1723812].
879 Patrick DL, Martin ML, Bushnell DM, et al. Quality of life of women with urinary incontinence: further development of the incontinence quality of life instrument (I-QOL). Urology. Jan. 1999;53(1):71-6. [pmid: 9886591].
880 Stothers L. Reliability, validity, and gender differences in the quality of life index of the SEAPI-QMM incontinence classification system. Neurourol Urodyn. 2004;23(3):223-8. [pmid: 15098217].
881 Kelleher CJ, Cardozo LD, Khullar V, et al. A new questionnaire to assess the quality of life of urinary incontinent women. Br J Obstet Gynaecol. Dec. 1997;104(12):1374-9. [pmid: 9422015].
882 Mouritsen L, Larsen JP. Symptoms, bother and POPQ in women referred with pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):122-7. [pmid: 12851756].
883 Stach-Lempinen B, Kirkinen P, Laippala P, et al. Do objective urodynamic or clinical findings determine impact of urinary incontinence or its treatment on quality of life?. Urology. Jan. 2004;63(1):67-71. discussion -2. [pmid: 14751350].
884 Stach-Lempinen B, Kujansuu E, Laippala P, et al. Visual analogue scale, urinary incontinence severity score and 15 D—psychometric testing of three different health-related quality-of-life instruments for urinary incontinent women. Scand J Urol Nephrol. Dec. 2001;35(6):476-83. [pmid: 11848427].
885 Amarenco G, Arnould B, Carita P, et al. European psychometric validation of the CONTILIFE: a Quality of Life questionnaire for urinary incontinence. Eur Urol. Apr. 2003;43(4):391-404. [pmid: 12667721].
886 Contreras Ortiz O, Lombardo RJ, Pellicari A. Non-invasive diagnosis of bladder instability using the Bladder Instability Discriminant Index (BIDI). Zentralbl Gynakol. 1993;115(10):446-9. [pmid: 8273434].
887 Klovning A, Hunskaar S, Eriksen BC. Validity of a scored urological history in detecting detrusor instability in female urinary incontinence. Acta Obstet Gynecol Scand. Nov. 1996;75(10):941-5. [pmid: 9003097].
888 Lemack GE, Zimmern PE. Predictability of urodynamic findings based on the Urogenital Distress Inventory-6 questionnaire. Urology. Sep. 1999;54(3):461-6. [pmid: 10475355].
889 Roongruangsilp U, Lertsithichai P, Kochakarn W, et al. Correlation between symptoms and urodynamic findings in Thai female patients with urinary incontinence. J Med Assoc Thai. Mar. 2005;88(3):364-70. [pmid: 15962645].
890 Brown JS, Bradley CS, Subak LL, et al. The sensitivity and specificity of a simple test to distinguish between urge and stress urinary incontinence. Ann Intern Med. May 16. 2006;144(10):715-23. [pmid: 16702587]. [pmcid: 1557357].
891 Bradley CS, Rovner ES, Morgan MA, et al. A new questionnaire for urinary incontinence diagnosis in women: development and testing. Am J Obstet Gynecol. Jan. 2005;192(1):66-73. [pmid: 15672005].
892 Seim A, Talseth T, Haukeland H, et al. Validation of a simple patient questionnaire to assist self-detection of overactive bladder. A study in general practice. Scand J Prim Health Care. Dec. 2004;22(4):217-21. [pmid: 15765636].
893 Rohr G, Christensen K, Ulstrup K, et al. Reproducibility and validity of simple questions to identify urinary incontinence in elderly women. Acta Obstet Gynecol Scand. Oct. 2004;83(10):969-72. [pmid: 15453896].
894 Gunthorpe W, Brown W, Redman S. The development and evaluation of an incontinence screening questionnaire for female primary care. Neurourol Urodyn. 2000;19(5):595-607. [pmid: 11002302].
895 Diokno AC, Dimaculangan RR, Lim EU, et al. Office based criteria for predicting type II stress incontinence without further evaluation studies. J Urol. Apr. 1999;161(4):1263-7. [pmid: 10081882].
896 Robinson D, Pearce KF, Preisser JS, et al. Relationship between patient reports of urinary incontinence symptoms and quality of life measures. Obstet Gynecol. Feb. 1998;91(2):224-8. [pmid: 9469280].
897 Sandvik H, Espuna M, Hunskaar S. Validity of the incontinence severity index: comparison with pad-weighing tests. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):520-4. [pmid: 16547687].
898 Cardozo L, Coyne KS, Versi E. Validation of the urgency perception scale. BJU Int. Mar. 2005;95(4):591-6. [pmid: 15705086].
899 Ficazzola MA, Nitti VW. The etiology of post-radical prostatectomy incontinence and correlation of symptoms with urodynamic findings. J Urol. Oct. 1998;160(4):1317-20. [pmid: 9751344].
900 Petros PP, Ulmsten U. Urge incontinence history is an accurate predictor of urge incontinence. Acta Obstet Gynecol Scand. Oct. 1992;71(7):537-9. [pmid: 1332374].
901 Kong TK, Morris JA, Robinson JM, et al. Predicting urodynamic dysfunction from clinical features in incontinent elderly women. Age Ageing. Jul. 1990;19(4):257-63. [pmid: 2220485].
902 Cantor TJ, Bates CP. A comparative study of symptoms and objective urodynamic findings in 214 incontinent women. Br J Obstet Gynaecol. Oct. 1980;87(10):889-92. [pmid: 7191720].
903 van Waalwijk van Doorn ES, Ambergen AW, Janknegt RA. Detrusor activity index: quantification of detrusor overactivity by ambulatory monitoring. J Urol. Feb. 1997;157(2):596-9. [pmid: 8996366].
904 Ding YY, Lieu PK, Choo PW. Is the bladder “an unreliable witness” in elderly males with persistent lower urinary tract symptoms?. Geriatr Nephrol Urol. 1997;7(1):17-21. [pmid: 9422435].
905 Digesu GA, Khullar V, Cardozo L, et al. Overactive bladder symptoms: do we need urodynamics?. Neurourol Urodyn. 2003;22(2):105-8. [pmid: 12579626].
906 McInerney PD, Vanner TF, Harris SA, et al. Ambulatory urodynamics. Br J Urol. Mar. 1991;67(3):272-4. [pmid: 2021814].
907 Hanzal E, Berger E, Koelbl H. Reliability of the urethral closure pressure profile during stress in the diagnosis of genuine stress incontinence. Br J Urol. Oct. 1991;68(4):369-71. [pmid: 1933156].
908 Rosario DJ, MacDiarmid SA, Radley SC, et al. A comparison of ambulatory and conventional urodynamic studies in men with borderline outlet obstruction. BJU Int. Mar. 1999;83(4):400-9. [pmid: 10210561].
909 Bergman A, Nguyen H, Koonings PP, et al. Use of fetal cardiotocographic monitor in the evaluation of urinary incontinence. Isr J Med Sci. Jun. 1988;24(6):291-4. [pmid: 3403225].
910 Sutherst JR, Brown M. Detection of urethral incompetence. Erect studies using the fluid-bridge test. Br J Urol. Aug. 1981;53(4):360-3. [pmid: 7196273].
911 Davis G, McClure G, Sherman R, et al. Ambulatory urodynamics of female soldiers. Mil Med. Dec. 1998;163(12):808-12. [pmid: 9866358].
912 Richardson DA. Value of the cough pressure profile in the evaluation of patients with stress incontinence. Am J Obstet Gynecol. Oct. 1986;155(4):808-11. [pmid: 3766634].
913 Swift SE, Ostergard DR. Evaluation of current urodynamic testing methods in the diagnosis of genuine stress incontinence. Obstet Gynecol. Jul. 1995;86(1):85-91. [pmid: 7784028].
914 Summitt RL Jr, Stovall TG, Bent AE, et al. Urinary incontinence: correlation of history and brief office evaluation with multichannel urodynamic testing. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1835-40. discussion 40–4. [pmid: 1615993].
915 Versi E. Discriminant analysis of urethral pressure profilometry data for the diagnosis of genuine stress incontinence. Br J Obstet Gynaecol. Mar. 1990;97(3):251-9. [pmid: 2334653].
916 Pajoncini C, Costantini E, Rociola W, et al. The maximum urethral closure pressure and the Valsalva leak point pressure in the diagnosis of intrinsic sphincter deficiency: preliminary results. Acta Urologica Italica. 1999;13:231-5.
917 Cucchi A. Acceleration of flow rate as a screening test for detrusor instability in women with stress incontinence. Br J Urol. Jan. 1990;65(1):17-9. [pmid: 2310926].
918 Hsu TH, Rackley RR, Appell RA. The supine stress test: a simple method to detect intrinsic urethral sphincter dysfunction. J Urol. Aug. 1999;162(2):460-3. [pmid: 10411057].
919 Lobel RW, Sand PK. The empty supine stress test as a predictor of intrinsic urethral sphincter dysfunction. Obstet Gynecol. Jul. 1996;88(1):128-32. [pmid: 8684745].
920 Jolic V, Gilja I. Vaginal vs. transabdominal ultrasonography in the evaluation of female urinary tract anatomy, stress urinary incontinence and pelvic organs static disturbances. Zentralbl Gynakol. 1997;119(10):483-91. [pmid: 9361397].
921 Bergman A, McKenzie CJ, Richmond J, et al. Transrectal ultrasound versus cystography in the evaluation of anatomical stress urinary incontinence. Br J Urol. Sep. 1988;62(3):228-34. [pmid: 3056562].
922 Ouslander JG, Simmons S, Tuico E, et al. Use of a portable ultrasound device to measure post-void residual volume among incontinent nursing home residents. J Am Geriatr Soc. Nov. 1994;42(11):1189-92. [pmid: 7963206].
923 Dietz HP, McKnoulty L, Clarke B. Translabial color Doppler for imaging in urogynecology: a preliminary report. Ultrasound Obstet Gynecol. Aug. 1999;14(2):144-7. [pmid: 10492875].
924 Fantl JA, Newman DK, Colling J, et al. Managing acute and chronic urinary incontinence. Clinical Practice Guideline. Quick Reference Guide for Clinicians, No. 2, 1996 Update. Rockville, MD: U.S. Department of Health and Human Services, Public Health Service, Agency for Health Care Policy and Research; January 1996.
925 Hoerger TJ, Harris R, Hicks KA, et al. Screening for type 2 diabetes mellitus: a cost-effectiveness analysis. Ann Intern Med. May 4. 2004;140(9):689-99. [pmid: 15126252].
926 Messelink B, Benson T, Berghmans B, et al. Standardization of terminology of pelvic floor muscle function and dysfunction: report from the pelvic floor clinical assessment group of the International Continence Society. Neurourol Urodyn. 2005;24(4):374-80. [pmid: 15977259].
927 Bug GJ, Kiff ES, Hosker G. A new condition-specific health-related quality of life questionnaire for the assessment of women with anal incontinence. Bjog. Oct. 2001;108(10):1057-67. [pmid: 11702838].
928 Hiller L, Radley S, Mann CH, et al. Development and validation of a questionnaire for the assessment of bowel and lower urinary tract symptoms in women. Bjog. Apr. 2002;109(4):413-23. [pmid: 12013162].
929 Lukacz ES, Lawrence JM, Buckwalter JG, et al. Epidemiology of prolapse and incontinence questionnaire: validation of a new epidemiologic survey. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):272-84. [pmid: 15856132].
930 Frudinger A, Halligan S, Bartram CI, et al. Assessment of the predictive value of a bowel symptom questionnaire in identifying perianal and anal sphincter trauma after vaginal delivery. Dis Colon Rectum. Jun. 2003;46(6):742-7. [pmid: 12794575].
931 Wexner SD, Jorge JM. Colorectal physiological tests: use or abuse of technology?. Eur J Surg. Mar. 1994;160(3):167-74. [pmid: 8003569].
932 Damon H, Henry L, Barth X, et al. Fecal incontinence in females with a past history of vaginal delivery: significance of anal sphincter defects detected by ultrasound. Dis Colon Rectum. Nov. 2002;45(11):1445-50. discussion 50–1. [pmid: 12432289].
933 Stojkovic SG, Balfour L, Burke D, et al. Role of resting pressure gradient in the investigation of idiopathic fecal incontinence. Dis Colon Rectum. May. 2002;45(5):668-73. [pmid: 12004218].
934 Monk DN, Mills P, Jeacock J, et al. Combining the strength-duration curve of the external anal sphincter with manometry for the assessment of faecal incontinence. Br J Surg. Oct. 1998;85(10):1389-93. [pmid: 9782022].
935 Rao SS, Patel RS. How useful are manometric tests of anorectal function in the management of defecation disorders?. Am J Gastroenterol. Mar. 1997;92(3):469-75. [pmid: 9068472].
936 Felt-Bersma RJ, Klinkenberg-Knol EC, Meuwissen SG. Anorectal function investigations in incontinent and continent patients. Differences and discriminatory value. Dis Colon Rectum. Jun. 1990;33(6):479-85. discussion 85–6. [pmid: 2351000].
937 Dobben AC, Terra MP, Slors JF, et al. External anal sphincter defects in patients with fecal incontinence: comparison of endoanal MR imaging and endoanal US. Radiology. Feb. 2007;242(2):463-71. [pmid: 17255418].
938 Siproudhis L, Sebille V, Pigot F, et al. Lack of effficacy of botulinum toxin in chronic anal fissure. Aliment Pharmacol Ther. Sep 1. 2003;18(5):515-24. [pmid: 12950424].
939 Nelson R. Non surgical therapy for anal fissure. Cochrane Database Syst Rev 2006; (4):CD003431.
940 Nelson R. Operative procedures for fissure in ano. Cochrane Database Syst Rev 2005; (2):CD002199.
941 Shaikh S, Ong EK, Glavind K, et al. Mechanical devices for urinary incontinence in women. Cochrane Database Syst Rev 2006; (2):CD001756.
942 Wyman JF. Management of urinary incontinence in adult ambulatory care populations. Annu Rev Nurs Res. 2000;18:171-94. [pmid: 10918936].
943 Milne JL, Moore KN. Factors impacting self-care for urinary incontinence. Urol Nurs. Feb. 2006;26(1):41-51. [pmid: 16562385].
944 Chen SY. The development and testing of the pelvic floor muscle exercise self-efficacy scale. J Nurs Res. Dec. 2004;12(4):257-66. [pmid: 15619176].
945 Broome BA. Development and testing of a scale to measure self-efficacy for pelvic muscle exercises in women with urinary incontinence. Urol Nurs. Dec. 1999;19(4):258-68. [pmid: 10889770].
946 Bartlett L, Nowak M, Ho YH. Reasons for non-disclosure of faecal incontinence: a comparison between two survey methods. Tech Coloproctol. Sep. 2007;11(3):251-7. [pmid: 17676265].
947 Hagglund D, Walker-Engstrom ML, Larsson G, et al. Reasons why women with long-term urinary incontinence do not seek professional help: a cross-sectional population-based cohort study. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):296-304. discussion. [pmid: 14618304].
948 Kinchen KS, Burgio K, Diokno AC, et al. Factors associated with women's decisions to seek treatment for urinary incontinence. J Womens Health (Larchmt). Sep. 2003;12(7):687-98. [pmid: 14583109].
949 Lukaz K. Urinary incontinence: suffering in isolation. Can Nurse. May. 1995;91(5):23-6. [pmid: 7757932].
950 Huard J, Yokoyama T, Pruchnic R, et al. Muscle-derived cell-mediated ex vivo gene therapy for urological dysfunction. Gene Ther. Dec. 2002;9(23):1617-26. [pmid: 12424614].
951 Chancellor MB, Yoshimura N, Pruchnic R, et al. Gene therapy strategies for urological dysfunction. Trends Mol Med. Jul. 2001;7(7):301-6. [pmid: 11425638].
952 Chancellor MB, Yokoyama T, Tirney S, et al. Preliminary results of myoblast injection into the urethra and bladder wall: a possible method for the treatment of stress urinary incontinence and impaired detrusor contractility. Neurourol Urodyn. 2000;19(3):279-87. [pmid: 10797585].
953 Kerns JM, Shott S, Brubaker L, et al. Effects of IGF-I gene therapy on the injured rat pudendal nerve. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):2-7. discussion 8. [pmid: 12601508].
954 Melman A, Bar-Chama N, McCullough A, et al. hMaxi-K gene transfer in males with erectile dysfunction: results of the first human trial. Hum Gene Ther. Dec. 2006;17(12):1165-76. [pmid: 17134370].
955 Boyles SH, Weber AM, Meyn L. Ambulatory procedures for urinary incontinence in the United States, 1994-1996. Am J Obstet Gynecol. Jan. 2004;190(1):33-6. [pmid: 14749631].
956 Waetjen LE, Subak LL, Shen H, et al. Stress urinary incontinence surgery in the United States. Obstet Gynecol. Apr. 2003;101(4):671-6. [pmid: 12681869].
957 Mavrantonis C, Wexner SD. A clinical approach to fecal incontinence. J Clin Gastroenterol. Sep. 1998;27(2):108-21. [pmid: 9754771].