# Executive Summary

## Introduction

The high prevalence of urinary (UI), ^1,^ ^2^ fecal (FI), ^3^ and combined ^4,^ ^5^ incontinence in long-term care (LTC) settings and in community dwelling adults ^6^ – ^9^ and the substantial impact of incontinence on quality of life ^10^ – ^12^ ^13,^ ^14^ underscores the need for more and better research on effective strategies to identify patients at risk ^15^ – ^17^ and clinical interventions to reduce the risk of incontinence. ^13,^ ^18^ – ^21^ Prevalence and risk factors depend on baseline physiological mechanisms, including weakness of pelvic floor muscles important for both UI and FI, hyperactive bladder that may result in urge UI, poor urethral sphincter function associated with stress UI, ^22,^ ^23^ and impaired structural and functional integrity of pudendal nerve activity, rectal compliance and rectal sensation, and anal sphincter associated with FI. ^17,^ ^20,^ ^23,^ ^24^

Updated evidence-based recommendations to detect high-risk subgroups and to diagnose and treat symptoms and baseline causes of incontinence could improve effective patient-centered health care. ^25^ – ^27^

This systematic review was commissioned as background material for an NIH/OMAR State-of-the-Science Conference on the Prevention of Fecal and Urinary Incontinence in Adults. The aims of this review are to synthesize the published evidence of effective methods to identify individuals at risk and patients with undiagnosed UI and FI in the community and in LTC settings and to compare the effectiveness of different clinical interventions to prevent the occurrence and progression of UI and FI in adults.

The following questions were developed for this review:

1 What are the prevalence and incidence of urinary and fecal incontinence in the community and long-term care settings? How does prevalence differ in race, ethnicity, and gender groups?
2 What are the independent contributions of risk factors for urinary and fecal incontinence, including age, functional impairment, institutionalization, parity, childbirth, and postpartum state, menopause, dietary factors, smoking, obesity, genetic factors, prostate disorders, dementia, psychiatric disorders, specifically depression, diabetes, urinary tract infection, chronic gastrointestinal conditions, cardiovascular and pulmonary diseases, gastrointestinal, gynecologic, and urological procedures, neurological disorders, such as stroke and spinal cord problems?
3 What is the evidence to support specific clinical interventions to reduce the risk of urinary and fecal incontinence?
4 What are the strategies to improve the identification of persons at risk and patients who have urinary and fecal incontinence?
5 What are the research priorities for identifying effective strategies to reduce the burden of illness in these conditions?

For Question 1 we reviewed population-based surveys of prevalence and incidence of incontinence in LTC settings and in the community. We compared the diagnostic accuracy of different questionnaires, scales, and instrumental methods to the methods that are believed to be the “gold standard” to detect incontinence in adults. For Question 2 we evaluated the absolute risk of incontinence in subpopulations with risk factors, including surgical procedures and specific diseases, and adjusted relative risk or odds ratios of incontinence in adults with different levels of risk factors. For Question 3 we synthesized the results of the randomized controlled clinical trials (RCTs) and large multicenter trials to determine which treatments resulted in better rates of cure and improvement in symptoms and quality of life. Severity (frequency and amount of involuntary leakage of urine and feces) and impact on quality of life of incontinence were analyzed from the published articles.

## Methods

Original epidemiologic studies from 1990 to 2007 that examined the risk of incontinence in adults were identified from the National Library of Medicine, CINAHL, and Cochrane Databases. Randomized controlled clinical trials and nonrandomized large multicenter trials (for FI) were reviewed to compare the effects of different treatments.

We use the terminology of the International Continence Society (ICS) of urinary (stress, urge, mixed) (Chapter 3), anal (flatus and fecal: solid, and liquid feces), and combined incontinence (Chapter 5). ^20,^ ^21,^ ^23^ To facilitate the discussion of fecal incontinence, we use the term fecal incontinence in the text to encompass both fecal and anal incontinence and in the evidence tables we use the exact definitions from the original reports. These two terms are frequently used interchangeably in the literature and create a great deal of confusion.

## Results

Of 6,097 potentially relevant articles, we found 1,077 articles eligible for analysis.

### Prevalence of Incontinence in LTC Settings

The prevalence of UI in nursing homes varied from 30 to 77 percent. ^2,^ ^28^ – ^31^ More than half of the residents were incontinent at admission, ^32^ while the estimated annual incidence rate was 20 percent for occasional urge and 14.5 percent for occasional stress UI. ^33^ The majority of women in LTC (60–78 percent) reported UI. ^28^ – ^30,^ ^32^ The prevalence of UI in men ranged from 23 to 72 percent. ^28^ – ^30,^ ^32^ Prevalence rates increased with advancing age in both men and women of all races. ^2,^ ^29,^ ^30,^ ^32^ One of the largest cross-sectional studies of 10,215 older nursing home residents found that 40 percent of the residents suffer from combined UI and FI. ^5^ Involuntary loss of solid or liquid feces was experienced by 46 percent of nursing home residents ^3^ with an annual incidence of 14 percent. ^4^ Eighty-three percent of nursing home residents with severe cognitive impairment had FI. ^34^

### Prevalence of Incontinence in Community Dwelling Adults

Large population-based studies reported that 9–22 percent of adults had UI, ^8,^ ^9,^ ^30,^ ^35^ – ^38^ with even higher rates (37 percent) in a recent study of 145,765 men and women 65 years and over. ^39^ Pooled analysis of 117 epidemiological studies of UI prevalence in community dwelling women ^7,^ ^8,^ ^30,^ ^35^ – ^148^ suggested that the prevalence of ever having UI increased from 21 percent in 19–44 year old (17 studies) to 34 percent in 45–64 year old (45 studies), and to 39 percent among elderly women (11 studies). Younger females reported UI in the past year less frequently (two studies), the prevalence increased to 35–41 percent among women 45–64 years (11 studies) and older than 65 years (13 studies). Elderly women reported UI in the past month (four studies) more often. Overall prevalence of monthly UI was the highest in elderly females (two studies) ^111,^ ^133^ and in women 45–64 years old (nine studies). ^43,^ ^45,^ ^46,^ ^62,^ ^116,^ ^124,^ ^132,^ ^133,^ ^148^ Weekly incontinence was experienced more often by women older than 65 years ^42,^ ^94,^ ^97,^ ^148^ and elderly women over 80. ^42^ Few studies reported daily UI, 5 percent of younger women (19–44 years old) ^96^ and 17 percent of women older than 65 years ^79^ reported having daily leakage. The prevalence of total UI increase in age categories from 19 percent in women 19–44 years (18 studies) ^57,^ ^64,^ ^68,^ ^69,^ ^75,^ ^80,^ ^85,^ ^86,^ ^92,^ ^96,^ ^98^ – ^100,^ ^119,^ ^130,^ ^133,^ ^145,^ ^148^ to 29 percent in those older than 45 years. Stress incontinence was the most prevalent type in women 19–44 years old (15 studies) ^37,^ ^57,^ ^64,^ ^80,^ ^85,^ ^91,^ ^95,^ ^98,^ ^104,^ ^108,^ ^109,^ ^130,^ ^133,^ ^145,^ ^124^ and in those 45–64 years of age (36 studies). ^37,^ ^38,^ ^44,^ ^51,^ ^57,^ ^61,^ ^70,^ ^73^ – ^75,^ ^77,^ ^78,^ ^80,^ ^84,^ ^85,^ ^87,^ ^89,^ ^95,^ ^104,^ ^108,^ ^116,^ ^117,^ ^122,^ ^124,^ ^127,^ ^129,^ ^131,^ ^135^ – ^137,^ ^139,^ ^141,^ ^145,^ ^148,^ ^149^ However, mixed UI was the most prevalent type of incontinence in older women; 16.8 percent of women older than 65 (19 studies) ^30,^ ^35,^ ^59,^ ^66,^ ^71,^ ^72,^ ^74,^ ^80,^ ^85,^ ^90,^ ^104,^ ^106,^ ^108,^ ^110,^ ^121,^ ^128,^ ^142,^ ^143,^ ^145^ and 16 percent of elderly women reported mixed UI (seven studies). ^71,^ ^74,^ ^80,^ ^84,^ ^106,^ ^124,^ ^133^ The prevalence of urge incontinence gradually increased from 5 percent in younger women ^37,^ ^57,^ ^64,^ ^80,^ ^85,^ ^91,^ ^95,^ ^98,^ ^101,^ ^104,^ ^108,^ ^130,^ ^133,^ ^145^ to 10 percent in women 45–64 (32 studies), ^37,^ ^44,^ ^51,^ ^57,^ ^61,^ ^70,^ ^73^ – ^75,^ ^77,^ ^78,^ ^80,^ ^84,^ ^85,^ ^87,^ ^89,^ ^95,^ ^102,^ ^104,^ ^108,^ ^116,^ ^117,^ ^124,^ ^126,^ ^127,^ ^129,^ ^131,^ ^137,^ ^139,^ ^145,^ ^148,^ ^149^ and to 12 percent in women older than 65 years (28 studies). ^30,^ ^35,^ ^37,^ ^56,^ ^59,^ ^61,^ ^63,^ ^66,^ ^71,^ ^72,^ ^74,^ ^80,^ ^84,^ ^85,^ ^90,^ ^104,^ ^106,^ ^108,^ ^110,^ ^118,^ ^121,^ ^123,^ ^125,^ ^128,^ ^133,^ ^142,^ ^143,^ ^145^

Pooled annual incidence of UI (18 studies) ^38,^ ^45,^ ^47,^ ^56,^ ^59,^ ^62,^ ^103,^ ^134,^ ^139,^ ^149^ – ^157^ was 6.25 percent for all ages, with the highest in elderly women; 7 percent in those older than 65 years and 8.52 percent in women over 80. Overall, middle aged and elderly women developed stress UI more often (four studies). Annual incidence of mixed UI was close to stress UI (two studies). Less than 7 percent of women 45–79 years old developed urge UI (three studies).

Pooled analysis detected a clear pattern of increased prevalence of total UI in aging men from 5 percent in those 19–44 years old (11 studies) to 11 percent in those 45–64 years old (27 studies), to 21 percent in males over 65 years of age (41 studies). The highest prevalence of UI was reported in elderly males of 32 percent (17 studies). Urge UI was the most prevalent type of UI in males among all age categories, increasing from 3 percent in those 19–44 years old (7 studies) to 12 percent in those older than 65 years of age (20 studies) The prevalence estimations varied substantially depending on the definitions, with the higher prevalence of UI during the last year in American males 19–44 years old (18 percent) and 45–64 years old (25 percent) compared to UI during the last month. Older American males reported UI during the last month more frequently, from 29 percent among those older than 65 years of age to 42 percent in elderly males. Stress UI ever was experienced by 2 percent of American men 45–64 years old, 1 percent reported stress UI during the last month, and 1 percent during the last year. Urge UI was the more prevalent during the last year (7 percent of men 45–64 years old). Men over 65 years of age reported having urge UI during the last month (11 percent). Pooled analysis estimated that daily UI was experienced by 5 percent of males 45–64 years, 8 percent of men over 65 years old, and 9 percent of elderly men. Severe UI that required change of underwear was reported by 2 percent of those 45–64 years old and 4 percent of elderly men.

Combined UI and FI is experienced by 3 percent ^111^ to 6 percent ^158^ of older adults in the community. The prevalence of FI increased with age, ^111,^ ^159^ 3 percent of adults had daily leakage of feces; ^159^ weekly FI was reported by 4–5 percent ^159,^ ^160^ and monthly FI by 7 percent. ^159^ Pooled prevalence of FI in community dwelling men (22 studies) varied across the studies depending on definitions of incontinence and population characteristics. The lowest prevalence of anal incontinence (AI) of 2 percent was reported in two studies with median age of participants between 45 and 64 years. The prevalence of FI was less than 10 percent in all age groups and increased from 6 percent in those 45–64 years old to 10 percent in elderly men. The prevalence of solid feces incontinence was reported by 1 percent of men 45–64 years of age and by 2 percent of elderly males. The most prevalent was combined incontinence in elderly, 16 percent of men over 80 years experienced UI and FI. Prevalence of AI was the highest in women compared to other definitions and increased from 22 to 45 percent with aging (38 studies). An inclusion of flatus incontinence in the definition may contribute to an increased prevalence estimates in females. Prevalence of FI was higher than in males and increased from 7 percent in those 45–64 to 10 percent among elderly women. UI and FI were experienced by 10–12 percent of women. Severity of FI in females increased with age. ^161^ The prevalence of monthly FI varied from 6 percent ^162^ to 25 percent; ^125^ 1 percent ^162^ to 5 percent ^163^ of women had more than one FI episode per month. The prevalence of weekly FI was less than 7 percent in the majority of the studies. ^125,^ ^160,^ ^161,^ ^163^ Less than 2 percent of community dwelling women reported daily FI. ^125,^ ^161^

### Risk Factors for Incontinence in LTC

The residents of LTC with cognitive impairment, ^1,^ ^34^ physical dependency, ^4,^ ^29,^ ^34,^ ^164,^ ^165^ prolonged institutionalization, ^28^ diabetes, ^29,^ ^34^ and FI ^29^ had higher prevalence of UI. The odds of UI increased by 24 percent with each 5 years of age among LTC residents, ^4,^ ^165^ by 20–40 percent after stroke, ^4,^ ^165^ by 300–400 percent in adults with impaired activities of daily living (ADL), ^4,^ ^164^ and by 700 percent among wheelchair users and bedridden residents. ^29^ Women in LTC experienced UI more often than males. ^29,^ ^165^ FI was associated with 10 ^29^ to 20 ^165^ times larger odds of UI. Dependence in daily activities was associated with 6–7 times higher odds of FI, and dependency in eating with four times higher odds of FI. ^3^ Increased length of stay in nursing homes from 2 weeks to 1 year was associated with a seven times higher prevalence of FI. ^166^ Limited evidence suggested that the prevalence of combined UI and FI was twice as high in non-White as White residents of nursing homes. ^4,^ ^5^

### Risk Factors for Incontinence in Community Dwelling Adults

The prevalence of UI in men with prostate cancer was less than 10 percent in the majority of the studies. ^167^ – ^174^ UI rates after radical prostatectomy in 12,079 Medicare beneficiaries decreased from 20 percent in 1991 to 4 percent in 1995, being the highest in older patients. ^175^ Age was an independent risk factor for male UI in two studies. ^58,^ ^97^ Non White men had the same rates of UI compared to Whites. ^175^ Two studies showed that sedentary life was associated with UI in males. ^83,^ ^92^ Alcohol intake ^72,^ ^83,^ ^84,^ ^92^ and smoking ^72,^ ^83,^ ^92^ did not show a significant association with male UI. Males with diabetes had significantly higher adjusted rates of UI ^58,^ ^72,^ ^86,^ ^97,^ ^176^ with a pooled odds ratio of 1.4. Co morbidities and poor general health were associated with UI in several studies. ^81,^ ^84,^ ^92,^ ^97^ Males with arthritis had higher adjusted odds of total ^86^ or urge UI. ^176^ Memory problems, epilepsy, and neurological diseases were associated with higher rates of UI. ^4,^ ^58,^ ^72,^ ^86,^ ^97,^ ^114,^ ^176^ – ^178^ Stroke was shown as a strong and independent risk factor for UI in nursing home residents ^4^ and in community dwelling males ^58,^ ^86,^ ^97,^ ^176,^ ^177^ with pooled odds ratio of 2. Restrictions in activities of daily living were associated with higher crude and adjusted odds of UI in males in all studies that examined the relationship. ^4,^ ^81,^ ^92,^ ^97,^ ^106,^ ^114^ Males with urologic symptoms ^72,^ ^170,^ ^174,^ ^179^ or urinary tract infections had higher adjusted rates of UI with a pooled odds ratio of 3.5. ^72,^ ^74,^ ^92,^ ^97,^ ^106^ Men with prostate diseases had higher rates of UI after adjustment for confounding factors in the majority of the studies. ^72,^ ^83,^ ^92,^ ^170,^ ^176,^ ^180^ – ^183^

Age tends to be linearly associated with female UI prevalence and incidence rates. ^7,^ ^41,^ ^53,^ ^55,^ ^56,^ ^62,^ ^65,^ ^80,^ ^81,^ ^83,^ ^85,^ ^99,^ ^105,^ ^133,^ ^138,^ ^143,^ ^184^ Prevalent UI significantly increased with age in 20 ^7,^ ^55,^ ^66,^ ^67,^ ^73,^ ^74,^ ^81,^ ^84,^ ^92,^ ^96,^ ^97,^ ^105,^ ^118,^ ^124,^ ^133,^ ^138,^ ^149,^ ^185^ – ^187^ of 28 studies that reported the association. ^7,^ ^55,^ ^62,^ ^66,^ ^67,^ ^73,^ ^74,^ ^81,^ ^84,^ ^92,^ ^93,^ ^95^ – ^97,^ ^105,^ ^118,^ ^124,^ ^132,^ ^133,^ ^138,^ ^140,^ ^144,^ ^149,^ ^185^ – ^189^

The evidence of the association between race and incident UI is limited to two studies ^123,^ ^149^ being higher in Whites. African American women had higher odds of incident urge but lower odds of incident stress UI. Hispanic women developed weekly UI more often compared to Caucasians. Prevalence of mild, moderate, and severe UI was lower among African American women than White women in all six studies that examined the association. ^93,^ ^105,^ ^137,^ ^138,^ ^149,^ ^189^ Prevalence of moderate UI was lower among Hispanic women compared to Caucasian women in four of five studies. ^93,^ ^105,^ ^138,^ ^149,^ ^189^

Obesity was associated with higher incidence of UI in women in two studies. ^103,^ ^149^ Prevalent urge UI showed a positive dose response association in individual studies. ^51,^ ^133^ The strength of the association varied depending on definitions of UI. Adjusted odds of UI in the past month were higher in overweight and obese females. ^83,^ ^92,^ ^133,^ ^143^ Weekly UI was more prevalent in obese but not overweight women with a dose response increase per one unit of BMI. ^66,^ ^90,^ ^92,^ ^96,^ ^138,^ ^189^ With the definition of UI in the past year, the majority of the studies showed a significant increase in UI ^7,^ ^51,^ ^59,^ ^68,^ ^72,^ ^144^ and daily UI corresponding to an increase in BMI per one unit. ^55,^ ^67,^ ^70,^ ^149,^ ^189^ Obese women had greater odds of at least monthly UI compared to women with normal weight. ^67,^ ^104,^ ^121,^ ^124,^ ^138,^ ^149,^ ^190^ Daily and weekly stress UI were significantly associated with an increase in BMI in all studies that examined this association. ^51,^ ^66,^ ^70,^ ^118,^ ^132,^ ^133,^ ^135,^ ^149,^ ^187^

One large prospective cohort, the Nurses' Health Study, reported that intensive physical activity in women 50–79 years of age was associated with a significant reduction in incident total UI and stress UI. ^156^ Higher education was associated with increased odds of prevalent UI in several studies. ^67,^ ^70,^ ^72,^ ^83,^ ^93,^ ^149,^ ^189,^ ^191^ Six studies ^92,^ ^93,^ ^138,^ ^186,^ ^189,^ ^192^ of 12 ^67,^ ^72,^ ^83,^ ^92,^ ^93,^ ^138,^ ^143,^ ^186,^ ^189,^ ^191,^ ^192^ found a significant positive association between smoking and UI but the effect was not consistent in dose response models.

The studies of impaired cognitive function reported conflicting results about the association with incident ^147,^ ^186^ or prevalent UI. ^97,^ ^114,^ ^132,^ ^186^ Prevalence of UI was significantly higher in depressed women in five studies ^90,^ ^124,^ ^149,^ ^189,^ ^191^ of eight ^90,^ ^97,^ ^106,^ ^118,^ ^124,^ ^149,^ ^189,^ ^191^ that examined the association in multivariate analysis. Decreased physical function measured by self report and physical performance was significantly associated with UI in six studies ^67,^ ^81,^ ^92,^ ^97,^ ^144,^ ^189^ of eight ^67,^ ^81,^ ^92,^ ^97,^ ^106,^ ^132,^ ^144,^ ^189^ that examined this association.

The association between parity and UI in females was examined in 24 observational studies. ^55,^ ^59,^ ^64,^ ^68,^ ^70,^ ^72,^ ^83,^ ^92,^ ^93,^ ^95,^ ^96,^ ^105,^ ^119,^ ^124,^ ^133,^ ^135,^ ^138,^ ^149,^ ^185,^ ^191,^ ^193^ – ^196^ Incident UI was not associated with parity.149,193 A positive significant association between prevalent UI and parity was reported in 13 studies, ^68,^ ^72,^ ^83,^ ^93,^ ^96,^ ^105,^ ^119,^ ^124,^ ^138,^ ^185,^ ^191,^ ^193,^ ^195^ while six studies did not find a significant increase in prevalent UI in relation to parity. ^59,^ ^64,^ ^92,^ ^133,^ ^149,^ ^194^ The number of births did not show a dose response association with prevalent UI but did with moderate severe UI and severe UI. All six studies that measured prevalent stress UI reported a significant positive association with parity. ^72,^ ^95,^ ^133,^ ^149,^ ^195,^ ^196^ Prevalent stress UI and severe stress UI did not show a significant dose response association with the number of births. Only one study ^195^ of four ^72,^ ^133,^ ^195,^ ^196^ found an increase in urge UI corresponding to parity. The role of parity is complex and decreases as a woman ages. ^68,^ ^118,^ ^128,^ ^195^ Evidence suggests that UI developing during pregnancy is a risk factor for UI in the immediate postpartum period ^197^ and in subsequent years ^64,^ ^96^ raising the odds of UI by two to 11 times. ^96,^ ^198^

The association between UI and modes of delivery was conflicting. Cesarean section was associated with lower odds of UI in seven studies, ^119,^ ^197,^ ^199^ – ^203^ by 80 percent ^201^ to 41 percent ^200^ and did not show a significant association in five studies. ^135,^ ^141,^ ^196,^ ^204,^ ^205^ Two studies reported higher odds of UI when women after Cesarean section were compared with nulliparous females. ^7,^ ^206^ Few prospective studies reported protective effects of Cesarean section on UI compared to vaginal delivery. ^119,^ ^197,^ ^202,^ ^205^

Individual studies suggested that menopausal status can be associated with UI, increasing the odds by 127 percent ^93^ to 144 percent. ^191^ Five ^55,^ ^83,^ ^108,^ ^124,^ ^138^ studies of eight ^55,^ ^62,^ ^72,^ ^83,^ ^108,^ ^124,^ ^138,^ ^144,^ ^191^ that examined the association between UI and hysterectomy reported significantly higher adjusted rates of total UI among women after hysterectomy. The increase was 160 percent for UI in the past month, ^108^ 130 percent for at least monthly UI, ^124^ 140 percent for daily UI (OR 1.4, 95 percent CI 1.1, 1.6), ^55^ and 160 percent for severe UI. ^138^ Several epidemiological studies have examined estrogen therapy as a risk factor for UI. ^55,^ ^59,^ ^96,^ ^105,^ ^118,^ ^138,^ ^144,^ ^191^

Women with urinary tract infections had higher rates of UI in 11 studies ^66,^ ^72,^ ^74,^ ^90,^ ^92,^ ^97,^ ^108,^ ^116,^ ^121,^ ^127,^ ^144^ of 15 ^66,^ ^70,^ ^72,^ ^74,^ ^90,^ ^92,^ ^96,^ ^97,^ ^106,^ ^108,^ ^116,^ ^121,^ ^127,^ ^144,^ ^187^ that examined the association.

Evidence from three studies, ^7,^ ^86,^ ^118^ suggested that women with arthritis had higher rates of UI by 80–88 percent. ^7,^ ^86^ Two studies ^134,^ ^149^ of three ^134,^ ^149,^ ^186^ reported that women with diabetes develop UI more often. Incidence of weekly UI was higher by 147 percent in women with duration of diabetes more than 10 years. ^134^ The same Nurses' Health Study cohort showed that incidence of severe UI was increased by 175 percent and very severe by 262 percent. ^134^ The Study of Women's Health Across the Nation found a 302 percent increase in developing monthly UI in women with diabetes independent of other risk factors. ^149^ Prevalence of stress UI was greater in women with diabetes in three studies ^95,^ ^133,^ ^149^ of six ^66,^ ^95,^ ^108,^ ^133,^ ^135,^ ^149^ that examined the association with pooled odds ratios that were not significant. However, the majority of the studies reported a significant increase in adjusted odds of total UI among women with diabetes ^55,^ ^66,^ ^72,^ ^86,^ ^93,^ ^97,^ ^108,^ ^116,^ ^124,^ ^127,^ ^128,^ ^133,^ ^134,^ ^138,^ ^149,^ ^186^ (16 studies). Four of five studies found a significant increase in adjusted odds of urge UI among women with diabetes ^66,^ ^108,^ ^118,^ ^133,^ ^149^ (five studies).

One prospective cohort, the Canadian Study of Health and Aging, found that elderly community dwelling women had a higher risk of developing UI after stroke. ^207^ Prevalence of UI was significantly higher among women after stroke in five ^55,^ ^86,^ ^97,^ ^133,^ ^186^ of six ^55,^ ^67,^ ^86,^ ^97,^ ^133,^ ^186^ studies that examined this association (pooled OR 1.7). Women with two or more comorbid diseases had higher adjusted rates of UI. ^55,^ ^84,^ ^92,^ ^121,^ ^124,^ ^149,^ ^189^ Three studies ^68,^ ^121,^ ^144^ reported a significant increase in adjusted odds of UI in women with constipation among six studies that examined this association. ^68,^ ^74,^ ^97,^ ^121,^ ^144^

Consistent evidence showed that FI increased with age in women. ^208^ – ^213^ AI increased by 87 percent for every additional 10 years of age in Asians and by 36 percent in White females. ^187^ Maternal age older than 25 years was associated with greater odds of FI ^214^ and persistent FI. ^215^ The odds of FI increased by 271 percent after age 75. ^58^ Diabetes, ^58,^ ^216,^ ^217^ obesity, ^218^ and sedentary lifestyle were among risk factors for FI in community dwelling adults. ^125^ Adults with poor general health and comorbidities, ^163,^ ^219^ including kidney diseases, ^186^ transient ischemic attack, ^219^ and arterial hypertension ^213^ had higher odds of FI. Post stroke patients suffered from combined UI and FI five times more often ^58^ and from FI three ^216^ to five ^58^ times more often compared to adults without a stroke, with an increased risk in older adults, ^220^ diabetics, ^220^ and survivors with functional dependency after severe stroke. ^220,^ ^221^ Adults with functional limitations, ^222,^ ^223^ women with major depression, ^163^ older men with depression, ^219^ and adults with impaired cognitive status ^186,^ ^223,^ ^224^ had higher prevalence of FI. Constipation, ^187,^ ^212^ irritable bowel syndrome, ^187,^ ^211,^ ^212^ and hemorrhoid surgery in women were associated with increased odds of FI. ^211^ The adjusted rates of FI were higher by 240 percent ^225^ to 450 percent ^219^ in women with diarrhea, by 190 percent in irritable bowel syndrome patients, by 250 percent in females with anal fistula, by 140 percent after cholecystectomy, ^225^ and by 400 percent in adults with incomplete bowel evacuation. ^217^ ^224^ Women after previous gynecological surgery complained about AI 1.8 times more often. ^213^ Adjusted odds of FI increase by 4.6 times in females after perianal surgery. ^217^ The adjusted odds of FI in women with UI were two to six times higher compared to continent females. ^162,^ ^163,^ ^219,^ ^226^

Delivery of heavy babies, ^202^ FI during pregnancy, ^209^ increased number of births, ^215,^ ^226^ and high degree of perineal injury ^187,^ ^209,^ ^218,^ ^227^ – ^231^ were significant risk factors for FI. A dose response association was found between FI and number of births ^209,^ ^213,^ ^215,^ ^226^ and with degree of birth related perineal damage. ^228^ – ^230^ The adjusted odds of persistent FI were 3.2 times greater among women after four or more deliveries. ^215^ Women with birth related sphincter tears after perianal trauma had 230 percent ^209^ to 280 percent ^231,^ ^232^ higher rates of FI.

### Effects of Clinical Interventions on UI

Clinical interventions to reduce the progression of UI in adults in LTC settings. Conservative management programs improved UI in nursing home residents. ^233^ – ^237^ Individualized prompted voiding and intensive endurance and strength training exercises significantly improved the continence status of the residents. ^234^ A computerized quality management pathway would avoid progression of UI in 140 per 1,000 treated residents of nursing homes. ^238^ Limited evidence suggested that the number of patients continent at discharge after stroke was four times larger after active compared to conventional rehabilitation programs, which would result in 722 additional cases of continence per 1,000 treated adults with stroke. ^239^

Community-based conservative management programs. Urinary continence service in the community that included lifestyle advice, bladder, and pelvic floor muscle training for 6 months ^240^ increased the proportion of continent patients by 50 percent and patients with improved UI by 20 percent. With this community-based continence service, UI was improved in an additional 100 subjects per 1,000 subjects treated; quality of life improved in 90 subjects and satisfaction with present urinary symptoms in 110. ^240^ Complex community-based intervention implemened by registered nurses, occupational therapist, and public health educators ^241^ and a continence management program implemented by nurse continence advisers with physician expertise ^242^ were effective to reduce the severity of UI in females.

Behavioral intervention for primary prevention of UI in women. Continence rates after behavioral modification programs, including pelvic floor muscle training, bladder training, and individualized test of knowledge and adherence implemented in 359 postmenopausal, continent women 55 years and older to prevent UI, were the same compared to usual care at 12 months of followup (continence rate 37 percent vs. 28 percent) but resulted in an improvement rate 136 percent higher than standard care in one RCT. ^243,^ ^244^ Intensive lifestyle therapy to lose and maintain at least 7 percent of initial body weight and to engage in moderate-intensity physical activity reduced stress UI by 15 percent after 2.9 years of followup in the Diabetes Prevention Program RCT among 2,191 overweight pre-diabetic women with BMI ±24 kg/m^2^ (RR 0.85). ^245^

Clinical interventions for primary prevention of UI in pregnant women were examined in eight large RCTs with more than 100 women ^246^ – ^253^ and one smaller trial; ^254^ three RCTs reported continence rates with 3–10 months of followup. ^249,^ ^250,^ ^253^ Conservative advice about self-administered pelvic floor muscle training at 5, 7, and 9 months after delivery supplemented with bladder training did not change the risk of stress UI and tended to decrease the risk of severe UI at 12 months postpartum. ^251,^ ^252^ Continence rates after intensive exercise care ^253^ and self-administered perineal massage ^250^ were comparable to usual care. Pelvic floor muscle training with biofeedback and electrostimulation started at 9 weeks after vaginal delivery resulted in continence ten times more often compared to usual care at 10 months of followup. ^249^

Clinical interventions for primary prevention of UI in males with urological diseases. The behavioral interventions on UI in males with prostate diseases were examined in 12 RCTs ^255^ – ^266^ but only two ^257,^ ^261^ of eight trials with continence outcomes ^255,^ ^256,^ ^257,^ ^259,^ ^261,^ ^262,^ ^264,^ ^265^ reported significant benefit after pelvic floor muscle training with biofeedback compared to usual care. The highest continence rate (99percent) was reported in a large, well designed RCT of early pelvic floor muscle training and biofeedback in participants who had radical retropubic prostatectomy for localized prostate cancer at 1 year of followup with a small significant relative benefit compared to usual care (RR 1.1). ^257^ The relative effect in the same RCT was larger when continence status was measured with the International Continence Society male questionnaire specific for UI (RR 1.3). ^257^ Continence rates in the control groups were more than 60 percent across other RCTs with no statistically significant differences compared to active treatments. The comparative effectiveness of pelvic floor muscle training compared to usual care in males after different treatment options for prostate cancer requires future confirmation in well-designed RCTs.

Pelvic floor muscle training for secondary prevention of UI. A large body of evidence suggested beneficial effects of behavioral interventions on UI in females. ^267^ – ^287^ Pelvic floor muscle training resulted in continence in females more often than usual care in four ^275,^ ^280,^ ^288,^ ^289^ of ten trials that compared usual care with active treatments. ^275,^ ^280,^ ^281,^ ^288^ – ^292^ Pooled results of relative benefits of pelvic floor muscle training (RR 7.1) ^275,^ ^280,^ ^288,^ ^289^ and pelvic floor muscle training combined with biofeedback (RR 11.2) ^288,^ ^289^ were sensitive to one small RCT ^288^ with a 2 month followup. Pelvic floor muscle training combined with bladder training increased continence rates by 175 percent compared to usual care (pooled RR 1.8). ^243,^ ^280,^ ^290,^ ^291^

Electrical stimulation for secondary prevention of UI. Urinary continence 1–6 months after electrical stimulation in females was reported in seven RCTs. ^293^ – ^298^ Two RCTs that assessed continence at 6 months or more of followup failed to show significant benefit from electrical stimulation compared to continent services or medications. ^293,^ ^299^ Other RCTs also did not demonstrate significant relative benefit of electrical simulation compared biofeedback assisted training ^297^ or placebo. ^295,^ ^296,^ ^300,^ ^301^ Electrical stimulation would result in improvement in UI in 180 women per 1,000 treated. ^302^ Electrical stimulation would improve UI in more than 400 women per 1,000 treated compared to placebo. ^303^ Home-managed electrical stimulation with vaginal or anal stimulators would avoid 50 cases of UI per 1,000 treated women. ^304^ The rates of continence from urge UI were more than 70 percent in one RCT after functional magnetic stimulation ^298^ with significant relative benefit compared to sham stimulation in only one trial at 2 months of followup (RR 3.5). ^298^

Neuromodulation for secondary prevention of UI. In community dwelling adults the implantation of a multiprogrammable neurostimulator cured 47 percent of participants with urge UI ^305^ with significant relative benefit compared to standard medical therapy. ^305^ Sacral root neuromodulation resulted in urge continence more than nine times more often than conservative management with medications or pelvic floor muscle training (RR 9.86). ^306^ Sacral nerve stimulation would avoid 385 ^306^ to 430 ^305^ cases of urge UI per 1,000 treated adults.

Injectable bulking agents for secondary prevention of UI. The effects of different bulking agents for secondary prevention of female UI were examined in four RCTs with one study of more than 100 females ^307^ and several smaller trials ^308^ – ^310^ with 6 ^309^ to 12 months ^307,^ ^308,^ ^310^ of followup. However, only one RCT reported significant relative benefit in 63 women with stress UI at 12 months of followup after transurethral ultrasonography-guided injections of autologous myoblasts and fibroblasts compared to conventional endoscopic injections of collagen (RR 9.5). ^308^

Medical devices for secondary prevention of UI included Hodge pessary, ^311^ disposable intravaginal devices, ^312,^ ^313^ urethral plug, ^314^ and vaginal cones ^299,^ ^315,^ ^316^ in females and UroLume sphincteric stent ^317^ or penile compression devices in males. ^318^ Blocking urinary leakage using a urethral insert device with disposable applicator resulted in continence in 67 percent of women with mixed or stress UI but showed no relative benefit compared to a urethral insert with a sterile balloon device. ^313^ One RCT of 122 women with stress UI did not show differences in continence rates after vaginal cones compared to continence guard services at 6 months of followup. ^299^ Limited evidence suggested that medical devices resulted in modest improvement in UI, not better than other interventions in females ^299,^ ^311^ – ^313,^ ^315^ and in males. ^317,^ ^318^

Surgical interventions for primary prevention of UI in women. Among examined gynecological surgeries, intrafascial total abdominal hysterectomy significantly reduced the risk of urge UI compared to the extrafascial approach. ^319^ Total or subtotal abdominal hysterectomy resulted in comparable continence rates 1 year after the surgery. ^320^ Prolapse surgeries in continent women (negative stress test at baseline) were examined in two RCTs. ^321,^ ^322^ Cystopexy alone compared to cystopexy with posterior pubourethral ligaments plication resulted in the same rates of UI at 1 year of follow up. ^322^ Incidence of stress UI was several times higher after Burch colposuspension. Compared to colposacropexy without prophylactic colposuspension at 3 years of followup. ^321^

Surgical interventions for secondary prevention of UI in women. Tension-free vaginal tape and sling procedures resolved stress UI in more than 75 percent of treated women ^323^ – ^342^ with some evidence of greater relative benefit compared to Burch colposuspension. ^343^ Surgery with Burch colposuspension for stress UI resulted in continence in more than 75 percent of women in the majority of the studies ^344^ – ^361^ with inconsistent relative benefit when compared to other treatments. Few RCTs reported significant relative increase in objective cure at 1 year of followup after tension-free vaginal tape procedure compared to active treatment. ^330,^ ^331^ Burch retropubic urethropexy resulted in continence in more than 90 percent of women and provided the largest relative benefit compared to modified anterior colporrhaphy (RR 5.1) ^353^ and anterior colporrhaphy with Kelly plication (RR 1.4). ^345^ Burch colposuspension with abdominal hysterectomy compared to anterior colporrhaphy with vaginal hysterectomy resulted in higher continence rates (RR 1.6) in women undergoing surgery for primary stress incontinence and a concurrent grade 2 or 3 cystocele. ^362^

The largest relative benefits with more than 300 excessive cases of stress UI per 1,000 treated females were reported after pelvic floor muscle training compared to regular care, and Burch colposuspensions, and tension-free vaginal tape compared to other surgical procedures. Hormone replacement therapy increased the risk and progression of UI in postmenopausal females. A few studies demonstrated relative benefits of local estrogen administration on stress UI by 64 percent ^363^ and urge by 55 percent. ^364^

Hormone therapy for primary prevention of UI increased incident mixed UI by 50 percent (RR1.5) and incident stress UI in postmenopausal women by 80 percent (RR 1.8). ^365^ Incident urge UI increased by 30 percent and total UI by 40 percent (RR 1.4) after estrogen combined with progestin (RR 1.3). ^366^ Oral estrogen alone without progestin increased incident stress UI by 210 percent (RR 2.1) ^365^ and worsened UI by 530 percent (RR 5.3). ^367^

Hormone therapy for secondary prevention of UI. Urinary continence was reported in four RCTs that examined the curative effects of local hormone therapy on secondary prevention among incontinent women. ^364,^ ^368^ – ^370^ The highest rates of continence were reported after transdermal administration of an estrogen patch (100 percent) and estrogen gel (90 percent) among postmenopausal women with self-reported urinary symptoms. ^368^ Topical estrogen in suppositories or creams combined with physiotherapy and electrostimulation cured 22 percent of women 50–74 years of age with regular mild incontinence (>2 leakage episodes per month) compared to 0 percent after no hormone treatment. ^364^

Pharmacological agents for secondary prevention of UI. Clenbuterol was more effective to achieve continence in females with stress UI compared to placebo but not to pelvic floor muscle training. Extended release tolteradine for 2–12 weeks resulted in greater rates of cure or improvement compared to placebo in adults with overactive bladder syndrome. Duloxetin administered for 3–12 weeks in patients with predominantly stress UI improved UI, but the rates of continence did not differ from placebo. Long-term effects of medications combined with pelvic floor training on continence are unknown. Comparative effectiveness of combined treatments, including medication, requires future research.

### Clinical Interventions to Reduce the Risk of FI

Conservative management programs for secondary prevention of FI in LTC settings. Consistent benefits of conservative management programs, ^233^ – ^235^ integrated FI care, ^235^ and functional individualized endurance and strength-training exercises ^234^ on FI in nursing homes were reported in several studies.

Pelvic floor muscle training for primary prevention of FI was examined in one RCT of 747 women with postnatal UI. ^251,^ ^252^ Assessment by nurses of incontinence with conservative advice on pelvic floor muscle training at five, seven, and nine months after delivery reduced the risk of any FI by 51 percent at 1 but not 6 years after index delivery.

Dietary intervention for secondary prevention of FI was reported in one RCT of 42 adult volunteers with incontinent loose or liquid stools at least weekly. ^371^ Usual diet supplemented with 25g of Metamucil did not reduce the proportion of incontinent stools at 1 month of followup.

Pelvic floor muscle training with biofeedback for secondary prevention of FI. Sensory biofeedback training with pelvic floor muscle training resulted in control of feces (fecal continence) twice as frequently in women with FI after obstetric and sphincter trauma as pelvic floor muscle training alone, ^372^ which would prevent 382 cases of FI per 1,000 treated. Studies of behavioral treatments of FI reported less than 40 percent improvement in severity and quality of life related to FI. ^372^ – ^375^ Limited evidence suggested a significant reduction in FI after complex behavioral interventions, including lifestyle changes and exercises augmented with biofeedback. ^376^

Neuromodulation for secondary prevention of FI. Individualized sacral nerve continuous stimulation improved FI in 89 percent of patients with severe baseline FI compared to 17 percent after sham stimulation in one study, ^377^ resulting in an improvement in symptoms in 720 additional patients among 1,000 treated.

Pharmacological agents for FI. Few pharmacological interventions ^378^ – ^380^ resulted in fecal continence in more than 50 percent of patients but were not statistically better than placebo ^378,^ ^379^ or surgery. ^380^

Surgical interventions to repair external anal sphincter after acute obstetric trauma (primary prevention). Four RCTs compared end-to-end technique to overlapping repair of obstetric anal sphincter lacerations; ^381^ – ^384^ six reported patient outcomes with inconsistent benefit from end-to-end technique.

Early detection of anal sphincter tears immediately after vaginal delivery followed by surgical repair significantly reduced the risk of FI 3 months and 1 year postpartum in RCTs of 752 pregnant women. ^385^

Delivery interventions for primary prevention of FI. The effects of episiotomy were examined in two RCTs; ^386,^ ^387^ the effects of Cesarean or vaginal delivery were compared in two RCTs; ^388,^ ^389^ the effects of delayed or immediate pushing in the second stage of labor with epidural analgesia in one RCT; ^390^ and the effects of delivery by forceps or vacuum extractor in three RCTs ^391^ – ^393^ without significant relative benefit of instrumental compared to vaginal delivery.

Surgical interventions for primary prevention of FI. Of nine RCTs that compared different surgical techniques for hemorrhoidectomy, none reported significant relative FI benefits. ^394^ – ^402^ The effects of “chemical sphincterotomy” in patients with chronic anal fissure were analyzed in three RCTs, ^403^ – ^405^ with no significant result on FI.

The effects of surgical procedures on FI in adults with full-thickness rectal prolapse were evaluated in nine RCTs, ^406^ – ^414^ with no significant difference between treatments.

Different surgical techniques resulted in similar rates of FI in patients with anorectal abscesses, ^415^ fistula-in-ano, ^416^ – ^418^ and anal fissure. ^419^ – ^423^ Adjuvant radiotherapy for adenocarcinoma of the rectum ^424^ – ^426^ consistently increased the risk of FI in three RCTs, by 60 percent during the day (RR 1.6), by 90 percent during the night (RR 1.9), by 70 percent in utilization of pads (RR 1.7) compared to mesorectal excision, ^424^ and by 220 percent (RR 2.2) compared to the low anterior resection. ^424^

Surgical interventions for secondary prevention of FI. The implantation of artificial bowel sphincter reduced FI severity ^427^ in a multicenter, prospective, nonrandomized clinical trial of 115 patients. However, 25 percent experienced post surgical infection that required surgical revision and 37 percent needed reimplantations.

Gluteus maximus transposition did not show significant benefit compared to total pelvic floor postanal repair with anterior levatoroplasty on women with post obstetric FI. ^428^

One multicenter noncontrolled nonrandomized clinical trial (Dynamic Graciloplasty Therapy Study Group) reported significant improvements in quality of life (Medical Outcomes Study Short Form 36 physical function and social functioning) after dynamic gracioplasty. The proportion of continent stools among total number of stools of more than 50 percent was 62–56 percent in nonstoma patients at 12–24 months and 37.5–43 percent in stoma patients at 24 months of followup. ^429,^ ^430^

Surgical interventions used to treat ulcerative colitis ^431^ – ^434^ resulted in comparable fecal continence during the first 10 years after surgery, with an increased risk of FI during the longer period of followup. Clinical interventions resulted in comparable incidence and progression of FI in the majority of the RCTs with no clear evidence of better prevention of FI.

### Strategies to Improve Identification of Persons at Risk and Patients who have UI and FI

Few well-designed studies examined the strategies to detect incontinence in adults. Positive clinical history of UI was associated with a small likelihood of urodynamic UI in females. ^435^ – ^455^ Inconsistent evidence implied that diagnostic values of x-ray, ^456^ – ^461^ single channel urodynamic, ^462^ – ^465^ and Q-tip test measuring straining angle ^466^ – ^469^ are similar to multichannel urodynamics. Translabial Doppler ultrasound ^470,^ ^471^ and transrectal ultrasound for the evaluation of the bladder neck anatomy and urethrovesical junction ^472^ – ^477^ (stress UI was defined as rethrovesical junction drop during stress of ≥1cm) were comparable to fluoroscopy for the detection of urinary leakage during urodynamic investigation in community adults and residents of nursing homes. Despite differences in positive predictive likelihood ratios compared to “gold standard” of urodynamic testing, the number needed to screen to detect one case of UI was similar and consistent among the studies. Effectiveness of self-reported scales, professional assessment of clinical history, and ultrasound to detect UI in women was comparable to urodynamic and consistent across race, age, and socioeconomic groups. However, clinical history and diaries were used by less than half the incontinent patients who actively sought health care for UI. ^112,^ ^155,^ ^478^ Population-based surveys using validated scales ^447,^ ^479,^ ^480^ yielded predictive likelihood ratios and the number needed to screen to detect one case of UI comparable to clinical history ^435,^ ^436^ but also had lower cost ($36–$67 vs. $175–$255 respectively).

The diagnostic value of tests among different age, race, and socioeconomic status subgroups has not been well established; however, the prevalence of undiagnosed UI differed by 10–20 percent in such groups. ^146^ Therefore, screening programs should target patients at high risk of UI. Limited evidence suggests that the Resident Assessment Protocol included in the Minimum Data Set (MDS) had a definitive predictive likelihood ratio to diagnose UI in nursing home residents. ^481^ Self-reported questionnaires and scales have unsatisfactory validity to diagnose FI in adults. Anal ultrasonography has the largest diagnostic value to detect anal trauma in patients with FI. ^482^

## Discussion

Public awareness of incontinence, its risk factors, and possible treatment options may reduce the burden of incontinence. Consistent definitions of incontinence and measures of success are important to compare the results from different studies. Despite extensive efforts to standardize the definitions of incontinence, ^483^ the original studies produced a plethora of measures. They measured self-reported symptoms and signs of incontinence, severity, and quality of life related to incontinence, and objective instrumental evidence of leakage inconsistently within and across the studies. Ratings of success by doctors and patients about quality of life in FI were also different. ^484^ Objective measures of UI showed random changes in most RCTs and could not be recommended as a measure of success for primary and secondary prevention of UI. The objective improvements in selected physiological measures were not consistent after the same interventions and did not correlate with self-reported continence and reduction in severity of UI. ^322,^ ^330,^ ^485^ – ^491^ The effects of treatments on quantitative measures of incontinence, including frequency and amount of leakage, were less compared to qualitative improvements in symptoms.

Other systematic reviews analyzed predominantly self-reported cure and improvement in UI, practically omitting objective measures of incontinence still commonly used in individual studies. ^492^ – ^494^ One review of two clinical trials with urodynamic tests concluded that the data is not sufficient to propose this invasive and costly testing as a measure of success. ^495^ The association between physiological testing and patient perception of severity of incontinence and quality of life is weak. The relationships between objective physiological measures of incontinence that are related to quality of life and primary diseases resulting in incontinence need future investigation. Long-term continence should be the primary outcome for future RCTs to consider the most effective clinical interventions.

Previous reviews did not find anal manometry a good measure of success in reducing FI. ^496^ – ^500^ Anal manometry was not a good measure of success in clinical trials of FI showing random changes between active and control interventions. ^372,^ ^375,^ ^376,^ ^403,^ ^501^ – ^503^ Improvement in self-reported FI was inconsistent with changes in anal manometry. ^373,^ ^376,^ ^378,^ ^503^ Few trials demonstrated the same direction and effect of treatment on improvement in FI and objective measures of FI. ^372^ Composite outcomes, including both self-reported changes in severity of incontinence and physiologic parameters in a common scale may offer a better choice to measure success of clinical interventions. ^504,^ ^505^

The strength of evidence varied for the research questions in the present review. Studies of diagnostic methods had the lowest quality with few RCTs conducted. ^437,^ ^462,^ ^506,^ ^507^ Large population-based surveys reported prevalence of incontinence in age, gender, and race subgroups. ^8,^ ^9,^ ^50,^ ^67,^ ^508^ The independent contribution of risk factors on UI and FI were analyzed with adjusted odds ratios in cross-sectional and retrospective cohort studies. However, multivariate models included different sets of risk factors. Since causality between risk factors and incontinence could not be determined from such studies and the majority of risk factors are not modifiable, we hesitated to estimate events attributable to risk factors. Efficacy and comparative effectiveness of clinical interventions to reduce the risk and progression of incontinence were analyzed from RCTs. The majority of the RCTs had good quality, did not exclude subjects from the analysis of the outcomes, and provided adequate randomization. However, allocation concealment was not adequate in a large proportion of RCTs. ^258,^ ^261,^ ^266,^ ^277,^ ^286,^ ^372,^ ^375,^ ^376,^ ^502,^ ^509^ – ^512^ The RCTs of interventions that are regulated by the FDA, including hormone replacement therapy, had the best quality. ^240,^ ^245,^ ^253,^ ^304,^ ^365,^ ^366,^ ^389,^ ^513,^ ^514^ Large RCTs, including weight reduction and increased physical activity, ^245^ complex conservative management of UI, ^240^ delivery management, ^388,^ ^389^ and early prevention of UI in postnatal care ^253^ also had high quality. Variations in populations, interventions, and measures of outcomes, rather than quality of RCT resulted in heterogeneity between studies.

## Conclusions

Epidemiologic surveys with behavioral risk factor surveillance systems are cost-effective to estimate the prevalence of urinary incontinence in large nationally representative population groups. Routinely collected clinical history should include an evaluation of the risk factors, symptoms, and signs of incontinence. Pregnant, obese, and aging women, women with vaginal prolapse, males treated for prostate disease, patients with rectal prolapse, and frail elderly and nursing home residents are high risk groups. Individualized management programs can improve continence in LTC facilities but are hard to sustain. Regular monitoring and documentation of the continence status in relation to implemented continence services should be quality of care indicators for nursing homes. Pelvic floor muscle and bladder training are effective to reduce the risk of incontinence. Preventive strategies might include assessment and reduction of modifiable risk factors in early stages of incontinence. Surgery is effective in curing stress UI in females. Clinical interventions for UI in males and for FI in adults need future investigation.

## Future Research

An important unresolved problem is clear definitions of the type of incontinence and patho-physiology of baseline conditions to have better estimations of prevalence and risk factors of incontinence. Inconsistencies between patient reports and physiological measures continue to pose a serious problem. ^484,^ ^515^ For efficacy studies, some combined measure might be applied, but for prevalence assessments, such an approach would pose serious logistical problems. Long-term effects of drugs, stimulators, and medical devices need future investigation in well-designed randomized trials. Given the social problems caused by incontinence, enthusiasm for surgical treatment remains high for treating both stress UI and FI, although future research is needed to examine the balance between benefits and harms related to surgery and the cost-effectiveness of surgical treatments compared to conservative interventions.

Managing both types of incontinence in LTC settings remains problematic. Programs that work under experimental conditions have not been sustained because they are labor intensive and essentially unreimbursed. Indeed, case mix based payments for nursing homes create a disincentive to manage incontinence.

Several other specific areas have been identified as needing more research. They include:

- Interaction between age, race, and other risk factors for UI and FI in women and men
- Effective strategies to prevent UI and FI in women and men in community and LTC settings
- Association between race and severity of UI and FI and quality of life related to UI and FI in men and women from the community and in LTC settings
- Strategies to reduce the risk of UI and FI related to pregnancy and childbirth
- Effectiveness of clinical interventions for incontinence by cognitive and physical functioning, gender, and ethnicity
- Long-term effectiveness of individual conservative therapies, conservative management programs, including community-based nonmedical interventions, and mechanical devices for UI and FI
- Comparative long-term effectiveness of conservative interventions, pharmacological interventions, combined conservative and pharmacological interventions, mechanical devices, and surgery for UI
- Individual patient factors that may modify the effects of different procedures
- Effects on FI of surgeries for hemorrhoids, rectal prolapse, rectal cancer, and anal fissures
- Effective strategies to identify patients at risk of UI and FI, including residents of LTC settings