# Acknowledgments

We would like to thank the librarians, Jim Beattie, M.L.I.S., Judy Stanke, M.A., and Delbert Reed, Ph.D., for their contributions to the literature search; Jing Du, Ryan Ping, Joseph Kaiya M.D., Susan Penque, and Mary Dierich for their assistance with the literature search and data abstraction; Marilyn Eells for editing and formatting the report; and Charmaine Bird and Kristina Mucha for assistance with data entry and formatting tables.

We also want to thank Linda Brubaker, M.D., Tomas Griebling, M.D., Robert Madoff, M.D., Richard Nelson, M.D., Joseph Ouslander, M.D., Neil Resnick, M.D., Carolyn Sampselle, Ph.D., David Thom, M.D., Ph.D., and Joanne Townsend, R.N., for serving on our Technical Expert Panel, Chadwick Huckabay, M.D., for advice and counsel on urinary incontinence management, and Ingrid Nygaard, M.D., Mary H. Palmer, Ph.D., and Debra Saliba, M.D., for reviewing the draft of this report and providing us with helpful recommendations for revisions and clarifications.