# Discussion

The present report synthesizes the evidence following the clinical pathway of detection, clinical diagnosis, treatment, and prevention of incontinence in community dwelling adults in and in LTC settings.

## Detection of UI

The first big challenge is to define what we call UI. Physiological and clinical self reports yield different results. A person with substantial symptoms despite no urodynamic signs of UI still has a substantial problem. The diagnostic detection rates from scales and clinical history for UI do not correlate closely to multichannel urodynamics. ^16^ The question is which should take precedence. Most of the evidence comes from women, with few studies for men. ^899,^ ^904^ The yield from screening is high, on average: two to four subjects should be screened to detect one case of UI. ^146^ A previous systematic review showed that in primary care settings clinical history and diaries are the most cost-effective methods to detect UI in women. ^16^ However, less than half the incontinent patients who actively sought health care for UI could provide clinical histories or use diaries. ^112,^ ^155,^ ^478^ Population-based surveys using validated scales ^447,^ ^479,^ ^480^ yielded predictive likelihood ratios and the number needed to screen to detect one case of UI comparable to clinical history ^435,^ ^436^ but at a lower cost ($36–$67 vs. $175–$255 respectively). Such population-based surveys can yield nationally representative valid estimations of prevalent and “bothersome” UI. Routine clinical examinations in high risk groups, including pregnant women and frail adults, should include assessment of UI.

The diagnostic value of the tests among different age, race, and socioeconomic status subgroups has not been well established; however, the prevalence of undiagnosed UI differed by 10–20 percent in such groups. ^146^ Therefore, screening programs should target patients at high risk of UI including aging and frail adults with functional dependency and cognitive impairment, patients with stroke, diabetes, obesity, poor general health, and comorbidities, pregnant females and women after vaginal birth or with vaginal prolapse, and males after urological surgery and radiation for prostate cancer. Limited evidence suggests that the Resident Assessment Protocol included in the MDS had a definitive predictive likelihood ratio to diagnose UI in nursing home residents. ^481^ Systematic evaluations of functional status of residents, including noninvasive examinations of incontinence without multichannel urodynamics, would be the preferable screening method in LTC settings.

## Detection of FI

Few validated questionnaires ^866^ and instrumental methods were examined to detect the presence and baseline of causes for FI ^17^ with no consensus on which test is the “gold standard,” essential to estimate the diagnostic values of other tests, ^926^ despite the tremendous impact of FI on quality of life and health care cost. ^17^ ^523^ Patient reports do not correlate well with anatomical and physiological measures. Anal manometry does not correlate well with ultrasonography ^932^ or sigmoidoscopy. ^935^ Endoanal ultrasound demonstrated the highest predictive likelihood ratio, ^482,^ ^937^ but the use of this method is restricted to adults seeking medical treatment. ^522,^ ^524^ The severity and impact of incontinence on quality of life can be estimated from self-reported frequency, amount of leakage, and restrictions on daily activities ^8,^ ^9,^ ^32^ but not from instrumental methods. ^483^ However, treatment decisions are made based on objective measures of incontinence. ^17,^ ^21^ Instrumental physiological measurements that are associated with patient outcomes and may reflect better effects of different interventions should be analyzed in well designed experiments.

## Treatment

The present report confirmed the significant diversity of interventions used, sampling strategies and definitions, and measurement of outcomes. ^17,^ ^21,^ ^25^

### Sampling

Studies of UI and FI in LTC facilities were limited to those that agreed to participate in clinical trials. ^233,^ ^234,^ ^238,^ ^708^ Recruitment of residents was restricted by cognitive function or comorbidities. ^709,^ ^710^ The loss of followup was substantial in most studies in LTC. ^233^ – ^235^ Studies of behavioral interventions among community dwelling adults relied largely on patients in clinics, ^250,^ ^372,^ ^501,^ ^510,^ ^712,^ ^714,^ ^716^ with few studies that reported population based recruitment. ^240,^ ^242,^ ^245^ Clinic-based sampling was used for most RCTs of surgical treatments of UI and FI among patients who decided to undergo surgery. Selection criteria varied for the same interventions. For example, only women with intact uteri were included in some, ^366,^ ^794,^ ^796,^ ^797^ but not all, RCTs ^367^ of hormone therapy. Studies that included continent subjects reported baseline leakage ^243,^ ^244^ and previous surgery for incontinence; ^761^ few excluded patients with a positive stress test. ^321,^ ^322^ Baseline characteristics of the patients were balanced with stratified randomization in several RCTs. ^379,^ ^400,^ ^712,^ ^771,^ ^788,^ ^800,^ ^803,^ ^808,^ ^837,^ ^938^ However, some clinical trials reported significant differences at baseline among treatment groups despite randomization. ^274,^ ^276,^ ^303,^ ^710,^ ^787,^ ^789^ Pooling analysis was questionable due to sampling differences in the present report and previous systematic reviews. ^529,^ ^536,^ ^539,^ ^546^ Applicability of clinical interventions that demonstrated significant improvement in incontinence was restricted to the sampled population groups. Whether these effective interventions would result in the same clinical benefit in other populations requires future research.

## Definitions of Incontinence and Measures of Success

Despite extensive efforts to standardize the definitions of incontinence, ^483^ the original studies measured self-reported symptoms and signs of incontinence, severity, and quality of life related to incontinence, and objective instrumental evidence of leakage inconsistently within and across the studies. The prevalence of stress (68.9 percent) was higher than the prevalence of any UI (45.5 percent) in the one report. ^122^ The Women's Health In the Lund Area study reported an increase in self-reported UI from 32 percent to an estimated 66 percent when the authors removed the restriction that the UI had to represent hygienic bother. ^131^ Another study estimated 20 cases of stress UI but 89 women answered positively to the question of urine leakges during coughing or sneezing. ^61^ Ratings of success including improvement in incontinence and in quality of life by doctors and patients were also different. ^484^ Objective measures of UI showed random changes in most RCTs. The objective improvements in selected physiological measures were not consistent after the same interventions and did not correlate with self-reported continence and reduction in severity of UI. ^322,^ ^330,^ ^485^ – ^491^ A small proportion of RCTs reported significant improvements in quality of life ^284^ and social adaptation ^288,^ ^299^ after behavioral interventions. Severity of UI and discomfort due to UI were reduced after pelvic floor muscle training with biofeedback in one RCT. ^729^ One RCT of a complex behavioral program supervised by nurse advisors and a consulting urogynecologist demonstrated improvement in quality of life using several scales. ^510^ Sacrocolpopexy with Burch colposuspension compared to other active treatments resulted in a small improvement in medical, epidemiological, and social aspects of aging scores for stress incontinence ^761^ and overall quality of life. ^353^ The effects of treatments on quantitative measures of incontinence, including frequency and amount of leakage, were less compared to qualitative improvements in symptoms.

Other systematic reviews analyzed predominantly self-reported cure and improvement in UI, omitting objective measures of incontinence. ^492^ – ^494^ One review of two clinical trials with urodynamic tests concluded that the data is not sufficient to propose this invasive and costly testing as a measure of success. ^495^

Previous reviews did not find anal manometry a good measure of success in reducing FI. ^496^ – ^500^ Anal manometry showed random changes between active and control interventions. ^372,^ ^375,^ ^376,^ ^403,^ ^501^ – ^503^ Improvement in self-reported FI was inconsistent with changes in anal manometry. ^373,^ ^376,^ ^378,^ ^503^ Few trials demonstrated the same direction and effect of treatment on improvement in FI and objective measures of FI. ^372^ Composite outcomes, including both self-reported changes in severity of incontinence and physiologic parameters in a common scale may offer a better choice to measure success of clinical interventions. ^504,^ ^505^

## Clinical Effectiveness to Reduce the Risk of Incontinence

### Primary Prevention

Few studies that reported inclusion of continent women at baseline also reported baseline urinary leakage ^243,^ ^244^ or previous surgery for UI in some participants; ^761^ only two RCTs excluded patients with a positive stress test. ^321,^ ^322^ The RCTs with primary prevention of incontinence did not always assess the continence status of the subjects at baseline and therefore, they cannot provide valid estimations of the preventive effects of the treatments. In many cases baseline conditions (prostate diseases in males and pregnancy in females), as well as examined interventions including delivery modes or prostate surgery, were associated with higher risks of incontinence. Without objective assessment of baseline incontinence we assumed that some of the participants may have had incontinence at baseline. To avoid bias at baseline status, we reviewed RCTs that equally distributed patients with diagnosed or undiagnosed (not reported in the articles) incontinence between active and control groups and thus provide valid estimates of the treatment effects. We also emphasized the effects of the treatments on continence, where continence was a well defined outcome and there was a clear goal to reduce the risk of incontinence in patients with either diagnosed or undetected (and hence not reported) incontinence.

Many surgical interventions reviewed here aimed to treat baseline conditions, including rectal cancer, anal fissures, ulcerative colitis, and hemorrhoids, reported incontinence as a secondary outcome to complications of surgery. We focused on the continence status only, rather than the primary therapeutic outcomes and surgical complications previously analyzed. ^557,^ ^939,^ ^940^ Therefore, we had to estimate the relative benefits attributable to these surgical procedures on reducing the risk of incontinence and improving quality of life. All clinically relevant outcomes should be taken into account when comparing the effectiveness of surgical procedures to treat cancer and other baseline diseases.

### Secondary Prevention

Clinical effectiveness to reduce the risk of incontinence included self-managed behavioral changes (especially pelvic floor muscle exercises), physiotherapy, pharmacological administration, use of medical devices, and surgery for UI and FI. Considerable variations in dose and length of interventions and followup periods and modifications of surgical techniques made overall comparisons across trials difficult and imprecise. The present report found a significant increase in continence after pelvic floor muscle training by 250 percent (RR 2.5, 95 percent CI 1.2; 5.3). Substantial heterogeneity between RCTs of biofeedback assisted pelvic floor muscle training and pelvic floor muscle training combined with bladder training was demonstrated in both the present and previous reviews. ^539,^ ^552^ Implemented behavioral changes did not show significant improvement in UI among residents in LTC settings in the analyzed trials and in previous assessments. ^528,^ ^529^

Despite substantial heterogeneity among studies, attributable benefit for public health can be estimated from individual RCTs. Compared to regular care, behavioral interventions could avoid 170–749 cases of stress UI per 1,000 treated. ^249,^ ^288^ Weight reduction would result in improved stress UI in 990 adults per 1,000 treated. ^714^ Intensive lifestyle changes would avoid 54 cases of stress UI per 1,000 treated. ^245^ Intensive supervised pelvic floor muscle training among pregnant women would prevent 390 cases of UI per 1,000 treated. ^246^

The largest attributable benefit on stress UI was demonstrated from small RCTs of 40–127 participants (Table 64). The effect size of pelvic floor muscle training on continence was smaller but still significantly better compared to usual care in the pooled analysis. The Cochrane systematic review reported better effects from pelvic floor muscle training on cure from single studies with no overall estimation. ^539^

This report confirms previous reviews of consistent significant benefits on female stress UI of laparoscopic and open colposuspension, ^492,^ ^494,^ ^535^ but inconsistent effects from containment products or mechanical devices to prevent urine leakage ^493,^ ^941^ and suburethral slings. ^343,^ ^546^ Future research may demonstrate more valid estimation of long-term benefits and harms after invasive treatments compared to early behavioral interventions when incontinence is minimal and does not affect the quality of life. We also attempted to review clinical interventions that could achieve total urinary continence (free from stress and urge UI) (Table 61). Limited evidence suggested that tension free vaginal tapes, ^328,^ ^340,^ ^770^ sling procedures, ^334,^ ^342^ and local estrogen therapy ^368^ can result in comparable benefits to colposuspension continence rates. ^486,^ ^775^ Not surprisingly, behavioral interventions provided the largest number of avoided cases of UI per 1,000 treated (Table 64). The role of early behavioral interventions to reduce the risk of incontinence in community dwelling adults has been intensively discussed in the medical literature. ^483,^ ^942^

The role of self-motivation to manage UI was beyond the scope of this review; however, some evidence suggests that individualized focus group interviews, ^943^ self-confidence in treatment benefits ^944^ and personal efficacy ^945^ may be associated with better outcomes.

We uncovered few well-designed RCTs among case series of clinical interventions for FI that demonstrated significant improvements, with conclusions similar to previous systematic analyses of evidence. ^496^ – ^500,^ ^549^ – ^557^ Conservative management of FI was effective in LTC. ^233^ – ^235^ Limited evidence suggests possible benefits from anal sphincter exercises and biofeedback therapy for women with obstetrically related FI. ^497^ Very few pharmacological interventions ^378^ – ^380^ resulted in fecal continence in more than 50 percent of patients and were not statistically better than placebo ^378,^ ^379^ or surgery. ^380^ Chemical sphincterotomy in patients with chronic anal fissure ^404,^ ^405^ resulted in a 100 percent continence rate. Different delivery modes and surgical techniques to repair obstetric anal sphincter lacerations demonstrated low clinical efficacy and comparable effectiveness. Surgeries for rectal prolapse achieved fecal continence in 40–56 percent with no significant differences between treatments. ^413,^ ^414^ The effect size of surgical procedures to treat FI varied depending on the definition of FI and baseline cause and severity of FI with no good evidence of the superior effectiveness of alternative surgical procedures. ^945^ Future well-designed research is necessary to examine surgical treatments of FI in different population groups. ^496^

## Strength of the Evidence

Studies of diagnostic methods had the lowest quality with few RCTs conducted. ^437,^ ^462,^ ^506,^ ^507^ Large-population-based surveys reported prevalence of incontinence in age, gender, and race subgroups. ^8,^ ^9,^ ^50,^ ^67,^ ^508^ The independent contribution of risk factors on UI and FI were analyzed with adjusted odds ratios in cross-sectional and retrospective cohort studies. Care must be taken to distinguish associations from actual risks. Moreover, many of the risks are immutable (e.g., age and gender) The temporality between these diseases and UI can be estimated from prospective cohort studies measuring the incidence of UI. Such studies have not yet been conducted. Observational studies cannot establish causality between comorbidities and UI. Adjusted odds ratio estimated probability of having incontinence among people with particular diseases compared to those without such diseases. The estimations are still valuable because they identify subgroups at higher probability of UI. However, multivariate models included different sets of risk factors. Since causality between risk factors and incontinence could not be determined from such studies, and the majority of risk factors are not modifiable, we hesitated to estimate events attributable to risk factors.

Efficacy and comparative effectiveness of clinical interventions to reduce the risk and progression of incontinence were analyzed from 365 RCTs. The quality of the RCTs was evaluated in terms of the preplanned intention to treat principle, masking of the treatment status, adequate allocation concealment, randomization scheme and adequacy, and justification for sample size. The majority of the RCTs showed good quality; did not exclude subjects from the analysis of the outcomes, and provided adequate randomization. However, allocation concealment was not adequate in a large proportion of RCTs. ^258,^ ^261,^ ^266,^ ^277,^ ^286,^ ^372,^ ^375,^ ^376,^ ^502,^ ^509^ – ^512^ The RCTs of interventions that are regulated by the FDA, including hormone replacement therapy, had the best quality. ^240,^ ^245,^ ^253,^ ^304,^ ^365,^ ^366,^ ^389,^ ^513,^ ^514^ Large RCTs, including the Diabetes Prevention Program, ^245^ complex conservative management of UI, ^240^ delivery management, ^388,^ ^389^ and early prevention of UI in postnatal care ^253^ had high quality.

RCTs remain a “gold standard” to establish causality of the treatments on the outcomes. Inadequate randomization and allocation concealment, exclusion of subjects from the analysis, and inadequate power to detect differences all threaten the validity of the results and waste time and resources. Central randomization, randomization of the clinics rather than patients, adequate allocation concealment, and preplanned intention to treat analysis are possible for all tested treatments. Variations in populations, interventions, and measures of outcomes, rather than quality of RCTs, resulted in heterogeneity between studies.

We did not include case series that described the experience of individual institutions to treat UI and FI (Chapter 25). ^21^ Such publications may be useful to generate hypotheses for well-designed trials but have poor internal and external validity and do not provide good evidence about comparative effectiveness of different treatments.

## Policy Implications

Public awareness of incontinence, its risk factors, and possible treatment options may reduce the burden on incontinence. The behavioral risk factor surveillance system may assess prevalence and annual incidence of incontinence in large nationally representative population groups. Routinely collected clinical history should include evaluation of the risk factors, symptoms, and signs of incontinence. Pregnant, obese, and aging women, males with prostate diseases, patients with vaginal and rectal prolapse, and frail elderly should be actively screened for incontinence. Quality indicators for nursing homes, including access to toilets and wet status of the residents, should be continuously monitored and analyzed. Instrumental methods, including multichannel urodynamics and anal manometry, cannot be recommended as outcomes to examine effectiveness of clinical interventions on incontinence. Early behavioral changes in weight, physical activity, and pelvic floor muscle training may reduce the incidence of incontinence in adults. Preventive strategies might include assessment and reduction of modifiable risk factors in early stages of incontinence when incontinence is minimal and does not affect the quality of life.

## Question 5. What are the Research Priorities for Identifying Effective Strategies to Reduce the Burden of Illness in these Conditions?

Future research should examine the reproducibility of effective clinical interventions, including local estrogen therapy, weight reduction combined with increased physical activity, individualized electrical and magnetic stimulation, sphincteric stents, penile compression devices, and artificial bowel sphincter. Several of these interventions are being tested in ongoing clinical trials registered in www.clinicaltrials.gov (Table 76). Consistency in long-term results would provide a better basis for clinical and policy decisions.

Table 76 Ongoing clinical trials of the interventions for incontinence (registered in www.clinicaltrials.gov)

Sponsors | Clinicaltrials.gov Identifier | Incontinence | Intervention Arms | | | | Phase
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK) | 00212264 | Postprostatectomy UI | Behavioral: behavior training | Device: biofeedback | Device: pelvic floor electrical stimulation | Behavioral: pelvic floor muscle exercise
Department of Veterans Affairs | 00292318 | FI | Behavioral: biofeedback
University of Pittsburgh | 00177541 | Urge UI | Behavioral: biofeedback, pelvic floor muscle training
University of Michigan | 00125177 | Stress UI | Behavioral: knack therapy | | | | I–II
NHS Health Technology Assessment Programme | 00237029 | UI after treatments for PC | Behavioral: pelvic floor muscle training | Behavioral: bladder training | Device: biofeedback | Behavioral: lifestyle changes
Norwegian Foundation for Health and Rehabilitation | 00271297 | Pelvic organ prolapse | Behavioral: pelvic floor muscle training
National Institute of Child Health and Human Development (NICHD) | 00270998 | UI | Behavioral: pelvic muscle training and exercises | Device: intravaginal incontinence pessary | Device: both pessary and pelvic muscle exercises | | III
University of British Columbia | 00323245 | UI | Behavioral: physiotherapy for urinary incontinence
Norwegian Fund for Postgraduate Training in Physiotherapy | 00476567 | Pregnancy-related diseases and complications during labor | Behavioral: regular exercise 45–60 minutes minimum three times per week
Hospices Civils de Lyon | 00387439 | AI | Behavioral: standard medical treatment + anoperineal physiotherapy | Behavioral: standard medical treatment
Queen's University | 00427778 | Stress UI | Device: incontinence ring (Milex) | | | | IV
Solace Therapeutics, Inc. | 00492596 | Stress UI | Device: AttenueX IntraVesical System | | | | III
Contura | 00333073 | UI | Device: Bulkamid - bulking agent
Ethicon, Inc. | 00453739 | Stress UI | Device: GYNECARE TVT-SECUR* System | Device: GYNECARE TVT* System | Device: GYNECARE TVT* Obturator System
William Beaumont Hospitals | 00441935 | UI | Device: InterStim Neuromodulation
CL Medical | 00442078 | UI | Device: I-STOP TOMS | Device: transobturator male sling | | | IV
Department of Veterans Affairs | 00345397 | FI in SCI | Device: percutaneous endoscopic colostomy tube
The Cleveland Clinic | 00475839 | Stress UI | Device: tension-free vaginal tape | | Device: Monarc subfascial hammock | | III
Austrian Urogynecology Working Group (AUWG) | 00441454 | UI | Device: tension-free vaginal tape (retropubic vs. transobturator)
South Glasgow University Hospitals NHS Trust | 00136071 | Stress UI | Device: transobturator tape-ARIS | Device: TVT-O
National Institute of Child Health and Human Development (NICHD) | 00460434 | Pelvic organ prolapse | Device: TVT
Uroplasty, Inc | 00448175 | Overactive bladder | Device: urgent PC | | | | IV
Medstar Research Institute | 00475540 | Pelvic organ prolapse | Device: vaginal mesh | | | | IV
Cellerix | 00475410 | Anal fistula | Drug: autologous adipose-derived stem cells (Cx 401) | | | | III
Urological Sciences Research Foundation | 00479596 | Overactive bladder | Drug: Botox | | | | II, III
National Institutes of Health (NIH) | 00178191 | UI | Drug: botulinum A toxin
Allergan | 00168454 | Overactive bladder UI | Drug: botulinum toxin type A | Drug: placebo | | | II
Allergan | 00439140 | Overactive bladder | Drug: botulinum toxin type A | | | | III
Allergan | 00311376 | Overactive bladder | Drug: botulinum toxin type A | | | | III
Allergan | 00461292 | Overactive bladder | Drug: botulinum toxin type A | | | | III
University of Rochester | 00345332 | Severe urge UI | Drug: botulinum-A toxin
Department of Veterans Affairs | 00223821 | UI | Drug: extended release oxybutynin chloride | Behavioral: behavior training
Asset Hospital Systems | 00498888 | Urge UI | Drug: tolterodine | Procedure: bladder training | Procedure: pelvic floor rehabilitation | Procedure: pelvic floor muscle training
Ion Channel Innovations | 00495053 | Overactive bladder | Gene Transfer: hMaxi-K | | | | I
University of Pittsburgh | 00177450 | UI | Procedure: acupuncture
National Center for Complementary and Alternative Medicine (NCCAM) | 00297427 | UI | Procedure: acupuncture
University Hospital of North Norway | 00303030 | FI | Procedure: anal injection of bulking agent | Procedure: biofeedback | | | I
The Cleveland Clinic | 00485355 | Hysterectomy for benign indications | Procedure: conventional laparoscopic hysterectomy | Procedure: robotic assisted laparoscopic hysterectomy
National Cancer Institute (NCI) | 00238381 | Colorectal cancer | Procedure: conventional surgery | Procedure: laparoscopic surgery | Procedure: surgery | | III
University Hospital, Rouen | 00213317 | FI | Procedure: cortical and lumbar-sacral magnetic stimulation
National Taiwan University Hospital | 00270738 | UI | Procedure: indirect training of the pelvic floor muscles via transversus abdominis
Central Carolina Surgery, PA | 00329862 | UI after laparoscopic adjustable gastric banding for morbid obesity | Procedure: laparoscopic truncal vagotomy
William Beaumont Hospitals | 00378664 | UI in SCI | Procedure: lumbar to sacral ventral nerve re-routing procedure | | | | II
Canadian Institutes of Health Research (CIHR) | 00187369 | Multiple pregnancy | Procedure: method of delivery (CS versus VB)
William Beaumont Hospitals | 00444730 | UI in PC | Procedure: radical prostatectomy | Procedure: interstim implantation
National Institute of Diabetes and Digestive and Kidney Diseases (NIDDK) | 00325039 | UI | Procedure: retropubic mid-urethral sling (TVT) | Procedure: transobturator mid-urethral sling (TVT-O and the Monarc) | | | IV
Assistance Publique - Hôpitaux de Paris | 00472069 | UI | Procedure: transplantation of the squeletic muscular cells | Procedure: surgery | Procedure: relation of the continence urinary
University of Calgary | 00234754 | Stress UI | Procedure: trans-vaginal tape, trans-obturator tape
Assistance Publique - Hôpitaux de Paris | 00231491 | Overactive bladder (OAB) | Drug: botulinum toxin A (Botox) | | | | II
Women's Health Clinical Research Center at the University of California, San Francisco | | UI | PRIDE (Program to Reduce Incontinence by Diet and Exercise) Diet, exercise, and weight loss | Regular care
University of Rochester | 00345332 | Severe urge UI | Drug: botulinum-A toxin | Placebo
Avera Pharmaceuticals | NCT00335660 | Overactive bladder | Drug: AV608, a neurokinin 1 (NK-1) antagonist | Placebo | | | II
GlaxoSmithKline | 00321477 | Overactive bladder | Drug: GW679769 | Placebo | | | II
University of L'Aquila | 00441428 | Overactive bladder and detrusor underactivity | Drug: solifenacin | Uncontrolled | | | II
University of Alabama at Birmingham | 00465894 | Overactive bladder postmenopausal | Drug: Detrol LA | Drug: estrace vaginal cream

Further investigation is needed on the long-term curative effects of self-reported continence of combined behavioral and drug therapies on clinical outcomes at 6 months or more followup rather than surrogate tests. The balance between the curative effects of surgical procedures for incontinence and adverse effects and costs should be further examined in well-designed RCTs. Administrative databases can provide useful information on comparative treatment effectiveness, but the results can be biased if provider characteristics are ignored.

The effectiveness of clinical interventions should be tested in subgroups of patients by race, comorbidities and concomitant treatments, and baseline functional conditions of the pelvic floor, including trauma and pelvic floor muscle strength. Better preplanned randomization schemes could yield sufficient numbers of patients among treatment groups to support subgroup analysis that would give valid estimations of treatment effects in different patient populations. The choice of outcomes should reflect patient perception of cure and quality of life rather than solely provider evaluation and instrumental testing.

The effects of early behavioral interventions in high risk populations on incidence of incontinence should be examined in well-designed RCTs. Pregnant and pre-menopausal continent women should be the target population for future preventive RCTs of complex lifestyle modification. The large proportion of incontinent adults who do not seek care requires changes in the public perception of incontinence as an embarrassing condition with no cure. ^946^ – ^949^ Clinical examination of pregnant women should include assessment of continence status. Pregnancy and postpartum care should include a quality indicator for continence evaluation. Continence service should be a quality indicator for health care during pregnancy and postpartum. Early detection of incontinence in annual population-based surveys (the Behavioral Risk Factor Surveillance System) may improve public awareness of incontinence. Several ongoing studies will test different diagnostic strategies to detect incontinence (Table 77).

Table 77 Ongoing studies of diagnosis of incontinence

Sponsor | Clinicaltrials.gov Identifier | Condition | Examined Strategy
Rambam Health Care Campus | 00437528 | Overactive bladder without incontinence, urge incontinence and voiding difficulties | Novel heat flow sensor unit for measuring urinary bladder capacity
Hospital de Clinicas de Porto Alegre | 00490438 | Before and after surgeries for UI | Measurement of vaginal squeeze pressure in incontinent patients
Tripler Army Medical Center | 00355433 | Non-pregnant females referred to the urogynecology clinic for bladder testing | Body and room temperature saline in urodynamics
Pfizer | 00481728 | Sympathetic skin response or heart rate variability as an objective biomarker of bladder sensation | Bladder sensation and changes in skin electrical conductance and heart rate

The pathophysiology of incontinence needs further investigation to develop effective preventive and curative treatments. Muscle-derived stem cells showed promising results in animal and in vivo studies. ^950,^ ^951^ Injections of myoblasts to bladder walls resulted in regeneration of myofibers and improved contractility. ^952^ Recombinant human insulin-like growth factor-I delivered with plasmid to denervated sphincter muscle improved recovery of sphincter function in animal models. ^953^ Gene transfer therapy with hMaxi-K was successfully tested in one Phase I clinical trial. ^954^ Another ongoing trial in patients with overactive bladder will examine the effects of gene therapy of the alpha subunit of the human smooth muscle Maxi-K channel (NCT00495053). Continence devices that work on demand, similar to cardiac pacemakers, may be developed in the future to prevent involuntary leakage of urine and feces.

An important continuing and unresolved problem is defining what is meant by either type of incontinence. The failure to resolve this issue impedes both prevalence and diagnostic and efficacy research. The inconsistencies between patient reports and physiological measures continue to pose a serious problem. For efficacy studies, some combined measure might be applied, but for prevalence assessments, such an approach would pose serious logistical problems. The differences are even more severe when one considers the implications of differences in utility weights applied to measures of incontinence between patients and clinicians. ^484,^ ^515^

The pressures for finding effective treatments have increased as a result of advertising of medications to treat UI that is directed to patients. Expectations have been raised. The need for more and better studies of treatments for both types of incontinence (UI and FI) remains. Given the social problems caused by incontinence, enthusiasm for surgical treatment remains high for treating both UI and FI, ^955^ – ^957^ although future research is needed to examine the balance between benefits and harms related to surgery and the cost-effectiveness of surgical treatments compared to conservative preventive interventions.

Managing both types of incontinence in LTC settings remains problematic. Programs that work under experimental conditions have not been sustained because they are labor intensive and essentially unreimbursed. Indeed, case mix based payments for nursing homes create a disincentive to manage incontinence.

Several other specific areas have been identified as needing more research. They include:

- Interaction between age, race, and other risk factors for UI and FI in women and men
- Effective strategies to prevent UI in women and men in community and LTC settings
- Effective interventions to reduce risk of institutionalization due to UI or FI.
- Association between race and severity of FI and quality of life related to FI in men and women from the community and in LTC settings
- Strategies to reduce the risk of FI related to pregnancy and childbirth
- Effectiveness of clinical interventions for incontinence across subgroups by cognitive and physical functioning, gender, and ethnicity
- Long-term effectiveness of individual conservative therapies, conservative management programs including community-based nonmedical interventions, and mechanical devices for UI and FI
- Comparative long-term effectiveness of conservative interventions, pharmacological interventions, combined conservative and pharmacological interventions, mechanical devices, and surgery for UI
- Individual patient factors that may modify the effects of different procedures
- Effects on FI of surgeries for hemorrhoids, rectal prolapse, rectal cancer, and anal fissures
- Cost-effective strategies to identify patients at risk of FI, including residents of LTC settings
- Long-term effects of conservative management programs for FI in community dwelling adults and residents of LTC settings