# Results

Figure 1 traces the flow of our literature search for Questions 1–4. We retrieved 6,038 potentially relevant references (5,938 from MEDLINE^®^, 16 from CINAHL, 22 from the Cochrane database and a manual search of the Cochrane reviews, and 63 from a manual search of other published reviews and articles). We excluded 71 percent of the retrieved studies; 40 percent were case series; 13 percent case reports; 5 percent studies with ineligible independent variables, 19 percent with no eligible outcomes, and 12 percent with ineligible target populations.

Figure 1. Flow of study selection

## Question 1. What are the Prevalence and Incidence of UI in the Community and LTC Settings?

### UI in the Adult Population (Appendix Table F1)

#### Overview

Fourteen epidemiological studies of UI prevalence in community settings have reported prevalence rates in a combined sample of adult women and men (Table 1). Five studies were conducted in the United States, ^8,^ ^30,^ ^39,^ ^54,^ ^120^ two studies in Sweden, ^37,^ ^114^ three studies in the United Kingdom, ^36,^ ^38,^ ^43^ and one study each in China, ^33^ the Netherlands, ^111^ Spain, ^35^ Japan, ^58^ and Australia. ^33^ The majority of these population-based surveys sampled middle-aged and older adult populations. Three studies included younger adults ages 18 years and over. ^36,^ ^37,^ ^54^ There are methodological and reporting differences among the studies. Some studies used mailed questionnaires, whereas others involved in-home interviews. Most studies reported on the actual prevalence of UI in the sample; however, one study extrapolated the prevalence estimate using census statistics for the entire United States population. ^8,^ ^9^ There is limited information available on the incidence, progression, and remission of UI in the adult population combining men and women.

Table 1 Prevalence of UI in community dwelling adults by age and race

Author Sample | Country | Ages (years) | Design | UI Definition | Response Rate (%) | Number | UI Prevalence (%)
Prevalence of UI in Adults (Women and Men Combined)
Miles, 2001 ^592^ | USA | 65 years & over | Population-based mailed survey | Difficulty holding urine | — | 2,660 | 14.1%
O'Brien, 1991 ^43^ | UK | 35 years & over | Population-based mailed survey | Urine leakage twice or more a month | 79 | 5,661 | 1,109 mild incontinence
| | | | | | | 784 regular incontinence
Lagace, 1993 ^54^ | USA | 20 years & over | Cross-sectional survey using self-administered questionnaire | Urine leakage over past 12 months | 86 | 2,830 | 33%
Nakanishi, 1997 ^58^ | Japan | 65 years & over | Population-based survey with in-home interview | Urine leakage | 95.4 | 1,473 | 9.8%
Damian, 1998 ^35^ | Spain | 65 years & over | Population-based survey with in-home interviews | Current involuntary urine leakage | 71.2 | 589 | 15.5%
Roe, 2000 ^36^ | UK | 18 years & over | Population-based mailed survey | Urine leakage ever | 53 | 6,319 | 9%
| | | | Regular UI: Twice or more a month
Liu, 2002 ^33^ | China | 70 years & over | Population-based survey with interview | Difficulty holding urine until getting to the toilet (urge UI) or accidentally passing urine (stress UI) | 53.4 | 2,087 | 17.4% Urge UI
| | | | | | | 4.4% Stress UI
| | | | | | | 20.6% Mixed UI
Adelmann, 2004 ^30^ | USA | 65 years & over | Population-based survey with in-home interview | Ever of current urine leakage or trouble holding urine in past 18 months | 59% with cooperation rate of 90% | 910 | 22.3%
Andersson, 2004 ^37^ | Sweden | 18–79 years | Population-based mailed survey | Urine leakage at least once a week or at any time | 64.5% | 9,836 | 19% any leakage
| | | | | | | 7% weekly leakage
Bogner, 2004 ^120^ | USA | 50 years & over | Population-based survey with in-home interview | Urine loss or having trouble getting to the bathroom on time within past 12 months | 42.8% of original sample | 822 | 22.4% White
| | | | | | | 6.3% Black
McGrother, 2004 ^38^ | UK | 40 years & over | Population-based mailed survey | Urine leakage either day or night | 60.2% | 92,491 | 16.1%
Stenzelius, 2004 ^114^ | Sweden | 75 years & over | Population-based mailed survey | Difficulty controlling urine during last 3 months | 50.3 | 4,227 | 39%
Teunissen, 2004 ^111^ | Netherlands | 60 years & over | Population-based mailed survey | Urine leakage twice or more a month | 88 | 5,748 | 19% (overall)
| | | | | | | 14% 60–64 years
| | | | | | | 16% 65–69 years
| | | | | | | 20% 70–74 years
| | | | | | | 26% 75–79 years
| | | | | | | 33% ≥80 years
Anger, 2006 ^8^ | USA | 60 years & over | Population-based survey using in-home interview | Difficulty controlling bladder including leaking small amounts of urine with coughing or sneezing over past 12 months | NA | 9,965 | 17% extrapolated from U.S. population
Mardon, 2006 ^39^ | USA | 65 years & over | Population-based mailed survey | Urine leakage in past 6 months | 76% | 145,765 | 37.3%
| | | | | | | 31.9% 65–69 years
| | | | | | | 34.0% 70–74 years
| | | | | | | 37.9% 75–79 years
| | | | | | | 41.1% 80–84 years
| | | | | | | 45.6% 85–90 years
| | | | | | | 49.3% 90–94 years
| | | | | | | 54.3% ≥age 95 years
| | | | | | | 30.6% Hispanics
| | | | | | | 37.9% Non-Hispanics
| | | | | | | 38.7% American Indians
| | | | | | | 31.6% Asians
| | | | | | | 30.3% African Americans
| | | | | | | 38.3% Whites
| | | | | | | 31.2% Other
Prevalence of UI in Women
Herzog, 1990 ^47^ | USA | 60 years & over | Population-based mailed survey | # days of urine lost in past 12 months | 66–72 | 1,154 | 37.7
Lagro-Janssen, 1990 ^46^ | Netherlands | 50–65 years | Population-based survey with in-home interview | Urine leakage more than twice a month | 60 | 1,442 | 22.5
Molander, 1990 ^48^ | Sweden | 65–84 years | Population-based mailed survey | Based on ICS definition | 70.1 | 4,206 | 16.9
Roe, 2000 ^36^ | UK | 18 years and over | Population-based mailed survey | Ever experienced urine leakage | 53 (male and female combined) | 2,699 | 11.3
Burgio, 1991 ^45^ | USA | 42–51 years | Cross-sectional survey with clinic and in home interviews | Urine leakage at least monthly | 60 | 541 | 58.4 at some time
| | | | | | | 30.7 on regular basis
Kok, 1992 ^42^ | Netherlands | 60 years & over | Population-based mailed survey | Urine leakage twice or more a week | 69 | 719 | 23.5 (weighted mean)
| | | | | | | 20.0 60–64 years
| | | | | | | 19.0 65–69 years
| | | | | | | 16.8 70–74 years
| | | | | | | 22.7 75–79 years
| | | | | | | 26.5 80–84
| | | | | | | 30.8 85–89 years
| | | | | | | 28.4 >90 years
O'Brien, 1993 ^43^ | UK | 35 years & over | Population-based mailed survey | Urine leakage twice or more a month | 79 (women and men combined) | 3,165 | 16.3 (overall)
| | | | | | | 16.1 35–44 years
| | | | | | | 16.6 45–54 years
| | | | | | | 16.7 55–64 years
| | | | | | | 14.1 65–74 years
| | | | | | | 18.0 ≥75 years
Rekers, 1992 ^41^ | Netherlands | 35–79 years | Population-based mailed survey | Urine leakage occurring at least weekly | 68% | 1,299 | 26.5 overall
| | | | | | | 5.9 daily
Brockelhurst, 1993 ^52^ | UK | 30 years & over | Cross sectional survey with in-home interviews | Ever have a bladder problems, e.g., leaking, wet pants, damp pants | Not reported | 2,224 | 14% were or had UI
| | | | | | | 9.3% in past year
| | | | | | | 7.5% in previous 2 months
Lagace, 1993 ^54^ | USA | 20 years & over | Cross sectional survey with self-administered questionnaire | Urine leakage in past 12 months | 86 | 826 | 43
Milsom, 1993 ^53^ | Sweden | 7 birth cohorts 1900-1940 | Population-based mailed survey | Not provided but based ICS definition | 74.6 | 7,459 | 16.8
Mommsen, 1994 ^51^ | Denmark | 30–59 years | Population-based mailed survey | Urine leakage over past year | 85 | 2,589 | 17
Seim, 1995 ^49^ | Norway | 20 years & over | Population-based mailed survey | Any frequency or amount of urine leakage | 77 | 1,820 | 29
Wetle, 1995 ^50^ | USA | 65 years & over | Population-based survey with in-home interview | Difficulty holding urine | 85 | 2,360 | 44
Brown, 1996 ^55^ | USA | 70 years & over | Cross-sectional survey with self-administered questionnaire | Urine loss during past 12 months | — | 7,949 | 41
Bogren, 1997 ^61^ | Sweden | 65 years & older | Population-based mailed survey | Involuntary urine loss | 92 | 225 | 28
Brieger, 1997 ^60^ | Hong Kong | Mean age 45 (SD 15) | Population-based telephone survey | Involuntary urine loss which is either socially or hygienically unacceptable | 43 | 1,054 | 13
Nakanishi, 1997 ^58^ | Japan | 65 years & over | Population-based with in-home interviews | Urine leakage | 95.4 | 1,405 (women not specified) | 9.8
Samuelsson, 1997 ^57^ | Sweden | 20–59 years | Cross-sectional mailed survey | Involuntary urine loss | 77 | 491 | 27.7
Thom, 1997 ^59^ | USA | 60 years & over | Population-based mailed survey | At least one episode of urinary incontinence in past year or having sought treatment | 74.7 | 939 | 72.6
Thom, 1997 ^59^ | USA | 65 years & over | Population-based using medical record and hospital records | UI diagnosis in medical record | — | 3,004 | 6.9% all ages
| | | | | | | 4.2% 65–74 years
| | | | | | | 7.3% 75–79 years
| | | | | | | 9.4% 80+ years
Damián, 1998 ^35^ | Spain | 65 years & over | Population-based survey with in-home interviews | Difficulty controlling urine or urine escaping | 71.2 (men and women combined) | 589 (men and women combined) | 64.2 (women)
Holtedahl, 1998 ^62^ | Norway | 50–74 years | Population-based survey with clinic interview | Any urine leakage, regular leakage with or without objective demonstration (≥2 episodes/month); and regular incontinence, ICS definition fulfilled | 72.6 | 507 | 47.3% any leakage (all ages)
| | | | | | | 42.7% 50–54
| | | | | | | 55.1% 55–59
| | | | | | | 44.8% 60–64 years
| | | | | | | 39.0% 65–69
| | | | | | | 56.1% 70–74 years
| | | | | | | 30.6% regular UI with or without objective demonstration
| | | | | | | 28.2% 50–54 years
| | | | | | | 29.9% 55–59 years
| | | | | | | 35.2% 60–64 years
| | | | | | | 24.4% 65–69 years
| | | | | | | 35.4% 70–74 years
| | | | | | | 18.9% regular UI, ICS definition
| | | | | | | 16.0% 50–54 years
| | | | | | | 20.6% 55–59 years
| | | | | | | 22.9% 60–64 years
| | | | | | | 17.1% 65–69 years
| | | | | | | 18.3% 70–74 years
Chiarelli, 1999 ^68^ | Australia | 18–23 years | Population-based mailed survey | Urine leakage in past year | 48% 18–23 years | 14,761 | 12.8 18–23 years
| | 45–50 years | | | 54% 45–50 years | 14,070 | 36.1% 45–50 years
| | 70–75 years | | | 41% 70–75 years | 12,893 | 35.0% 70–75 years
Dolan, 1999 ^65^ | Ireland | 35–74 years | Population-based mailed survey | Urine loss | 66 | 689 | 58
Foldspang, 1999 ^64^ | Denmark | 20–59 years | Population-based mailed survey | Urine leakage in past year | 75.5 | 4,710 | 17.7 overall
| | | | | | | 9.6 20–29 years
| | | | | | | 32.4 50–59 years
Fultz, 1999 ^67^ | USA | 70 years & over | Prospective cohort with in-person and telephone interviews | Urine loss in past 12 months | — | 3,385 White | 23.0% White
| | | | | | 606 Black | 16.2% Black
Hagglund, 1999 ^69^ | Sweden | 18–70 years | Population-based mailed survey | Involuntary urine loss at present time | 88 | 14,761 | 26 overall
| | | | | | | 12% 18–30 years
| | | | | | | 20% 31–40 years
| | | | | | | 32% 41–50 years
| | | | | | | 36% 51–60 years
| | | | | | | 28% 61–70 years
Kuh, 1999 ^70^ | UK | 48 years | Prospective cohort mailed survey | Urine leakage over past year | 93 | 1,378 | 55
Palmer, 1999 ^593^ | USA | 18 years & over | Cross-sectional mailed survey | Monthly urine leakage | 57% | 1,113 | 21%
Roe, 1999 ^594^ | UK | 18 years & over | Population-based mailed survey | Urine leakage at least twice a month | 52.4% | 3,356 | 11.3%
Stenberg, 1999 ^71^ | Sweden | 71 and 81 years | Population-based mailed survey | SUI, UUI, or MUI | 87 (71 years) | 2,245 | 46 (71 years)
| | | | | 62 (81 years) | 1,084 (71 years) | 45 (81 years)
| | | | | | 611 (81 years)
Swinthinbank, 1999 ^77^ | UK | 19 years & over | Cross-sectional mailed survey | Any urine leakage in past month; also ICS definition of UI interfering with social life or causing a hygienic problem | 80 | 2,075 | 69
| | | | | | | 30 (ICS definition)
| | | | | | | 55 19–39 years
| | | | | | | 76 40–59 years
| | | | | | | 71 60–79 years
| | | | | | | 76 80+ years
Bortolotti, 2000 ^72^ | Italy | 40 years & over | Population-based telephone survey | Urine leakage during past year | >99 | 2,767 | 11.4 overall
| | | | | | | 7.2 40–50 years
| | | | | | | 11.8 51–60 years
| | | | | | | 9.5 61–70 years
| | | | | | | 15.9 >70 years
Hannestad, 2000 ^80^ | Norway | 20 years & over | Population-based mailed survey | Any urine leakage | 80 | 27,936 | 25 overall
| | | | | | | 10% 20–24 years
| | | | | | | 14% 25–29 years
| | | | | | | 18% 30–34 years
| | | | | | | 21% 35–39 years
| | | | | | | 24% 40–44 years
| | | | | | | 28% 45–49 years
| | | | | | | 30% 50–54 years
| | | | | | | 28% 54–59 years
| | | | | | | 26% 60–64 years
| | | | | | | 27% 65–69 years
| | | | | | | 30% 70–74 years
| | | | | | | 34% 75–79 years
| | | | | | | 35% 80–84 years
| | | | | | | 35% 85–89 years
| | | | | | | 40% 90+ years
Iglesias, 2000 ^76^ | Spain | 65 years & over | Population-based survey with in-home-interview | Involuntary urine loss or wet underwear, clothes or bedclothes | 95 | 486 | 42
MacLennan, 2000 ^7^ | New Zealand | 15 years & over | Population-based survey with in-home interview | Urine leakage within past year | 51.3 | 1.546 | 35.3
Temml, 2000 ^75^ | Austria | 20 years & over | Cross-sectional survey with self-administered questionnaire | Involuntary urine loss within past 4 weeks | Not reported | 1,262 | 26.3 overall
| | | | | | | 4.1 20–39 years
| | | | | | | 10.8 30–39 years
| | | | | | | 22.9 40–49 years
| | | | | | | 34.9 50–59 years
| | | | | | | 36.9 60–69 years
| | | | | | | 36.0 70+ years
Tseng, 2000 ^79^ | Taiwan | 65 years & over | Population-based with in-home interview | Involuntary urine loss in daily life | 80 | 256 | 28
Ueda, 2000 ^74^ | Japan | 40 years & over | Population-based mailed survey | Any urine leakage | 52.5 (women and men combined) | 968 | 53.7
Maggi, 2001 ^81^ | Italy | 65 years & over | Population-based survey with in-home interview | Involuntary urine leakage ever | 89 | 1,531 | 22 (overall)
| | | | | | | 16.4 65–69 years
| | | | | | | 17.8 70–74 years
| | | | | | | 24.8 75–79 years
| | | | | | | 23.9 80–84 years
| | | | | | | 34.7 ≥90+ years
Muscatello, 2001 ^84^ | Australia | 41 years & over | Population-based computer-assisted telephone survey | SUI or UUI during past month | 68 | 262 | 61
Schmidbauer, 2001 ^83^ | Austria | 20 years & over | Cross-sectional with self-administered questionnaire and clinical assessment | Urine leakage during past 4 weeks | — | 1,262 | 26.3
Stoddart, 2001 ^82^ | UK | 65 years & over | Population-based mailed survey | Urine leakage in past month | 79 | 740 | 31 overall
| | | | | | | 29 65–69 years
| | | | | | | 22 70–74 years
| | | | | | | 31 75–79 years
| | | | | | | 42 ≥80 years
Bogner, 2002 ^88^ | USA | 50–96 years | Population-based mailed survey | Losing urine or having trouble getting to bathroom in past 12 months (ever) | 95 | 502 | 25.3
Buchsbaum, 2002 ^90^ | USA | 39–91 years | Cross-sectional survey with self-administered questionnaire | Current report of urine leakage | 78.4 | 149 | 49.7
Finkelstein, 2002 ^86^ | Canada | 30 years & older | Population-based mailed survey | Self-report or urinary incontinence diagnosed by a health professional | 93.6 | 29,520 | 2.5 per 100 for overall women (weighted estimated)
| | | | | | | 0.6 30–39 years
| | | | | | | 1.6 40–49 years
| | | | | | | 2.1 50–59 years
| | | | | | | 3.9 60–69 years
| | | | | | | 6.8 70–79 years
| | | | | | | 11.1 80+ years
Fitzgerald, 2002 ^188^ | USA | 16–69 years | Cross-sectional mailed survey | Urine loss when not able to get to toilet in time, when asleep, or when laughed, coughed, or sneezed | 54% | 269 | 29% monthly UI
| | | | | | | 88% White
| | | | | | | 11% Asian/Native American/Other
| | | | | | | <1% Black
Landi, 2002 ^94^ | Italy | 65 years & older | Population-based survey using Minimum Data Set for Home Care (MDS-HC) | Any involuntary urine loss regardless of amount ≥2 times/week | 97.2 | 2,658 | 63
Langa, 2002 ^595^ | USA | 70 years & over | Population-based survey with in-person interviews | Urine loss during past 12 months | — | 5,188 | 24%
Peyrat, 2002 ^85^ | France | 20–62 years | Cross-sectional survey with self-administered questionnaire | Current report of urine leakage | 60.7 | 1,700 | 27.5 (overall)
| | | | | | | 6% <25 years
| | | | | | | 18.2% 25–39 years
| | | | | | | 38.0% 40–55 years
| | | | | | | 47% >55 years
Sampselle, 2002 ^93^ | USA (7 cities) | 42–52 years | Population-based mailed survey | Urine leakage during past year | — | 3,302 | 56.9% (overall)
| | | | | | | 60.0% White
| | | | | | | 49.5% Black
| | | | | | | 50.2% Chinese
| | | | | | | 41.4% Hispanic
| | | | | | | 52.9% Japanese
Sze, 2002 ^89^ | USA | 15–91 years | Cross-sectional survey with self-administered questionnaire | Urine loss with exertion or urgency or use of pad or protected undergarment because of urine loss with exertion | Not reported | 2,370 | 41% White
| | | | | | | 31% Black
| | | | | | | 30% Hispanic
Van Oyen, 2002 ^92^ | Belgium | 15 years & over | Population-based survey with in-home interview | Loss of occurring bladder control sometimes | 60 | 3,804 | 4.6% (overall—weighted estimate)
| | | | | | | 0.2 % 15–24 years
| | | | | | | 1.8% 25–34 years
| | | | | | | 2.3% 35–44 years
| | | | | | | 3.8% 45–54 years
| | | | | | | 8.6% 55–64 years
| | | | | | | 11.7% 65–74 years
| | | | | | | 21.0% 75+ years
Araki, 2003 ^107^ | Japan | 40–92 years | Cross-sectional outpatient survey | Amount of urine leakage | 46% | 245 | 40
| | | | | (men and women combined)
Espino, 2003 ^110^ | USA | 65 years & over | Population-based survey with in-home interview | Urine loss during past 12 months | 90.5 | 1,589 | 15% Mexican Americans
Eva, 2003 ^99^ | Sweden | 40–60 years | Population-based mailed survey | Urine leakage weekly or more | 67 | 1,336 | 9% age 40
| | | | | | | 19% age 60
Grodstein, 2003 ^105^ | USA | 50–75 years | Prospective cohort with mailed survey | Urine loss during past 12 months | — | 83,168 | 17.7%
| | | | | | | 17.9% White
| | | | | | | 9.6% Black
| | | | | | | 15.6% Hispanic
| | | | | | | 12.5% Asian
Hunskaar, 2004 ^112^ | France, Germany, Spain, UK | 18 years & over | Cross-sectional mailed survey | Any urine leakage | 58.1 | 5,976 | 35% (overall)
| | | | | | | 23% Spain
| | | | | | | 44% France
| | | | | | | 41% Germany
| | | | | | | 42% UK
Hvidman, 2003 ^96^ | Denmark | 20–59 years | Population-based mailed survey | Urine leakage the preceding day | 60.3 | 2,158 | 18.3
Landi, 2003 ^97^ | Italy | 65 years & over | Population-based survey using Minimum Data Set for Home Care | Any involuntary urine loss regardless of amount ≥2 times/week | — | 3,194 | 52
Miller, 2003 ^100^ | Australia | 21–26 years | Population-based mailed survey | Urine leakage in past month | 50% 23–26 years | 934 | 89% overall
| | 48–53 years | | | 83% 48–53 years | | 77.4% 23–26 years
| | 73–79 years | | | 80% 73–79 years | | 95.4% 48–53 years
| | | | | | | 95.0% 73–79 years
Nuotio, 2003 ^106^ | Finland | 70 years & over | Population-based survey using interviews | SUI or UUI | 93 | 227 | 59 with any type of UI
Rortveit, 2003 ^98^ | Norway | 20–64 years | Population-based mailed survey | Any involuntary urine loss | 80 | 27,936 | 20.7
Adelmann, 2004 ^30^ | USA | 65 years & over | Population-based with in-home interviews | Positive response to one of 6 questions: trouble holding urine or leaking urine; losing urine when one coughs, sneezes, laughs, or with physical activity; losing urine on the way to the bathroom; frequently losing small amounts of urine; other kinds of urinary accidents; and ever having urinary accidents; or involuntary urine loss | 59 (women and men combined) | 308 | 45% ever/current UI
| | | | | | | 49% White
| | | | | | | 43% Black
| | | | | | | 31.9% Other
| | | | | | | 25.5% UI in past week
| | | | | | | 28.7% White
| | | | | | | 22.4% Black
| | | | | | | 16.4% Other
| | | | | | | Ever/current UI by age:
| | | | | | | 37.4% 65–74 years overall including 39.1% Whites, 36.4% Blacks,
| | | | | | | 47.7% 75–84 years, including 53.1% Whites, 50.0% Blacks
| | | | | | | 62.1% 85+ years overall; 53.1% Whites, 71.4% Blacks
| | | | | | | UI in past week by age:
| | | | | | | 20.4% 65–74 years overall including 22.9% Whites, 16.7% Blacks,
| | | | | | | 27.6% 75–84 years: including 23.3% Whites, 29.4% Blacks
| | | | | | | 36.3% 85+ years:
| | | | | | | 37.7% Whites, 42.9% Blacks
| | | | | | | Medically-detected UI 23.8%
Andersson, 2004 ^37^ | Sweden | 18–79 years | Population-based mailed survey | Urine leakage at any time or at least weekly | 64.5 (men and women combined) | 7,680 surveyed; response not provided | 11% weekly
| | | | | | | 3% 18–34 years
| | | | | | | 10% 35–49 years
| | | | | | | 13% 50–64 years
| | | | | | | 21% 65–79 years
| | | | | | | 27% at any time
| | | | | | | 10% 18–34 years
| | | | | | | 26% 35–49 years
| | | | | | | 37% 50–64 years
| | | | | | | 39% 65–79 years
Bogner, 2004 ^120^ | USA | 50 years and older | Population-based mailed survey | Difficulty losing urine or having trouble getting to bathroom in time (ever) | 95 | 502 | 19.8%
| | | | | | | 22.4% White
| | | | | | | 13% Black
Holroyd-Leduc, 2004 ^113^ | USA | 70 years & over years | Population-based survey using telephone and in-home interviews | Any amount of urine loss during past 12 months | 87.4 | 5,913 | 18.5
Hunskaar, 2004 ^112^ | France, Germany, UK, Spain | 18 years and over | Cross-sectional mailed survey | Based on ICS definition using symptoms in past 30 days | 60 France | 3,881 | 44% France
| | | | | 59 Germany | 3,824 | 41% Germany
| | | | | 64 Spain | 6,444 | 23% Spain
| | | | | 45 UK | 2,931 | 42% UK
Jackson, 2004 ^123^ | USA | 70–79 years | Prospective cohort with mailed self-administered questionnaire | Urine leakage during past 12 months | 98.4% of those who answered incontinence questions at baseline interview | 1,584 | 46%
Lagergren, 2004 ^115^ | Sweden | 65 years & over | Population-based survey with self-administered questionnaires and clinic examinations | Urine loss during the past 12 months with at least one episode in past month | 50–74 depending on region | 4,465 | 14
MacLennan, 2000 ^7^ | Australia | 15–97 years | Population-based with in-home interviews | Stress or urge UI | 73.3% | 1,546 | 35.3
McGrother, 2004 ^38^ | UK | 40 years & over | Population-based mailed survey | Urine loss with categorical scale determined for frequency and volume of loss | 60.2 | 50,002 | Of those with UI:
| | | | | | | 3.5% profound
| | | | | | | 11.8% severe
| | | | | | | 7.3% moderate
| | | | | | | 11.6% minimal
Østbye, 2004 ^186^ | Canada | 65 years & over | Population-based mailed survey | Ever lose bladder control or pass water | — | 5,322 | 19% (overall)
| | | | | | | 14.2% 65–68 years
| | | | | | | 15.9% 70–74 years
| | | | | | | 19.7% 75–79 years
| | | | | | | 25.0% 80–84 years
| | | | | | | 24.6% 85–89 years
| | | | | | | 29.0% 90+ years
Özerdogan, 2004 ^116^ | Turkey | 20 years & over | Cross-sectional mailed survey | Urine loss at least twice a month or more | — | 3,259 | 25.8%
Stenzelius, 2004 ^114^ | Sweden | 75 & over | Population-based mailed survey | Difficulty controlling urine during last 3 months | 61.6 | 2,636 | 41.6
Teunissen, 2004 ^111^ | Netherlands | 60 years & over | Population-based mailed survey | Involuntary urine loss twice or more a month | 88 | 3,159 | 29% (overall)
| | | | | | | 22% 60–64 years
| | | | | | | 26% 65–69 years
| | | | | | | 29% 70–74 years
| | | | | | | 36% 75–79 years
| | | | | | | 38% ≥80 years
Vandoninck, 2004 ^122^ | Netherlands | 29–79 years | Population-based mailed survey | Ever have involuntary urine loss | 73 | 1,071 | 40%
Bradley, 2005 ^125^ | USA | 57–84 years | Prospective cohort using self-administered questionnaire | Urine leakage in past 3 months | 88 | 297 | 85.2% (ever)
Jackson, 2005 ^128^ | USA | 55–75 years | Population-based with clinic interviews | Any urine leakage during past month | — | 1,017 | 60% past month
| | | | | | | 8% severe UI
Kocak, 2005 ^127^ | Turkey | 18 years & over | Population-based survey with in-home interview | SUI, UUI, or MUI | 98.8 | 1,012 | 23.9%
Lewis, 2005 ^596^ | ISA | 50–69 years | Population-based telephone or in-person interviews | Urine lost during past 12 months | — | 10,678 | 21.7%
| | | | | | | 57% mild UI
| | | | | | | 43% severe UI
Lifford, 2005 ^134^ | USA | 50–75 years | Prospective cohort with mailed questionnaire | Urine loss at least weekly | Not reported | 81,845 | 17.4%
Melville, 2005 ^124^ | USA | 30–90 years | Cross-sectional mailed survey | Urine leakage at least monthly | 64 | 3,536 | 42%
Nygaard, 2005 ^130^ | USA | 18–60 years | Cross-sectional mailed survey | Any leakage in previous 30 days | 68 | 2,210 | 38.6%
Oskay, 2005 ^121^ | Turkey | 50 years & over | Cross-sectional mailed survey | Involuntary urine loss either stress, urge, or mixed incontinence | Not reported | 500 | 68.8%
Rohr, 2005 ^133^ | Denmark | 45–68 years | Population-based survey with in-home interview | Leaking urine >1 time/month with either physical exertion strong urgency, or both | 91 | 5,795 | 32.6%
| | | | | | | 20.1%: <60 years
| | | | | | | 29.8%: 60–80 years
| | | | | | | 43.7%: ≥80 years
Ruff, 2005 ^126^ | USA | 19–82 years | Cross-sectional survey with self-administered questionnaire | Urine leakage or losing control of urination | 47 | 233 | 37.6% African American
Swanson, 2005 ^143^ | Canada | 45 years & over | Cross-sectional mailed survey | Urine loss when coughing, laughing, or with activity or before reaching toilet | 61.1 | 606 | 51.3%
| | | | | | | 51.7% 45–50 years
| | | | | | | 59.3% 51–55 years
| | | | | | | 55.9% 56–60 years
| | | | | | | 50.8% 61–65 years
| | | | | | | 52.2% 66–70 years
| | | | | | | 43.6% 71–75 years
| | | | | | | 45.0% 76–80 years
| | | | | | | 48.6% >81 years
Teleman, 2005 ^131^ | Sweden | 55–64 years | Population-based survey with self-administered questionnaire | Urinary leakage which causes a social and/or hygienic problem | 89% | 6,917 | 32%
Anger, 2006 ^8^ | USA | 60 years & over | Population-based mailed survey | Difficulty controlling bladder including leaking small amounts of urine with coughing and sneezing | Not reported | 9,965 | 38%
| | | | | | | 41% non-Hispanic White
| | | | | | | 20% non-Hispanic Black
| | | | | | | 36% Mexican-American
Brown, 2006 ^140^ | USA | 60 years & over | Population-based survey with in-home interview and physical examination | Weekly or more frequent urine leakage over past 12 months | NA | 1.461 | 16.8% normal glucose
| | | | | | 1,051 normal glucose | 33.4% impaired fasting glucose
| | | | | | 164 impaired fasting glucose | 35.4% diabetics
| | | | | | 246 diabetes
Danforth, 2006 ^138^ | USA (14 states) | Mean age 44.8 | Prospective cohort with mailed survey | Urine loss at least once a month or more during past 12 months | 82.3 | 83,355 | 43% Overall
| | | | | | | 44% White
| | | | | | | 36% Black
| | | | | | | 45% Hispanic
| | | | | | | 86% Asian
Irwin, 2006 ^145^ | Canada, Germany, Italy, Sweden, and UK | 18 years & over | Population-based survey using computer-assisted telephone interview | Frequency of urine leakage | 33% | 1,675 | 13.1%
| | | | | (women and men combined) | | 7.3% [6.5–8.1] ≤39 years
| | | | | | | 13.7% [12.6–14.9] 40–49 years
| | | | | | | 19.3% [17.9–20.7] ≥60 years
Jackson, 2006 ^144^ | USA | 55–75 years | Population-based survey with clinic interview | Accidental urine leakage during past year | 26% | 1,107 | 66%
| | | | | | | 8% severe incontinence
Mardon, 2006 ^39^ | USA | 65 years and over | Population-based mailed survey | Urine leakage in past 6 months | 67% | 86,708 | 43.6%
Tannebaum, 2006 ^142^ | Canada | 55 years & over | Population-based mailed survey | ICI questionnaire | 47% | 2,361 | 39%
Thom, 2006 ^137^ | USA | 40–69 years | Population-based survey with self-administered questionnaire and in-person interview | At least 1 self-reported episode of urine loss | 65.1% | 2,109 | Age-adjusted prevalence in past year (OR, 95% CI)
| | | | | | | White: 73.3, 71.4–75.2
| | | | | | | Hispanic: 74.8, 73.0–76.7
| | | | | | | Black: 64.8, 62.8–66.9
| | | | | | | Asian: 68.8, 66.9–70.8
| | | | | | | Age-adjusted prevalence in last week
| | | | | | | White: 27.2%
| | | | | | | Hispanic: 33.1%
| | | | | | | Black: 23%
| | | | | | | Asian: 18.5%
Wehrberger, 2006 ^139^ | Austria | 20–84 years | Prospective cohort mailed survey | Urine loss during past 4 weeks | 47.7% | 441 | 32%
Harris, 2007 ^146^ | USA | 30–79 years | Population-based survey with in-home interview | Weekly urine leakage | 63 | 331 | 10.3%
Huang, 2007 ^147^ | USA | 65 years & over | Prospective cohort with mailed survey | Urine leakage in past 12 months | NA | 6,361 | 53%
Huang, 2007 ^187^ | USA | 40–69 years | Population-based mailed survey | Weekly or daily urine leakage | — | 1,349 | White: 17.8% weekly, 13.0% daily
| | | | | | | Asian: 10.6% weekly, 7.8% daily
Kinchen, 2007 ^148^ | USA | 21–75 years | Population-based mailed survey or telephone interview | Urine leakage in the past 7 days | 49.7 | 3,344 | 44%
| | | | | | | 34.3% <50 years
| | | | | | | 50.4% 50–64 years
| | | | | | | 51.8% 65+ years
Waetjen, 2007 ^149^ | USA | 40–55 years | Prospective cohort with mailed survey | Urine loss during past year | — | 3,302 | 46.7% monthly loss
| | | | | | | 15.3% weekly loss
Prevalence of UI in Men
Herzog, 1990 ^47^ | USA | 60 years & over | Population-based mailed survey | Urine loss in past 12 months | 66–72% check | 802 | 18.9
O'Brien, 1991 ^43^ | UK | 35 years & over | Population-based mailed survey | Urine leakage at least twice a month | 79 (men and women combined) | 2,496 | 7.4 (overall)
| | | | | | | 2.4 35–44 years
| | | | | | | 5.5 45–54 years
| | | | | | | 5.7 55–64 years
| | | | | | | 12.1 65–74 years
| | | | | | | 15.4 ≥75 years
Brocklehurst, 1993 ^52^ | UK | 30 years & over | Population-based survey with in-home interview | Ever have a bladder problem, e.g., leaking, wet pants, damp pants | Not reported | 1,883 | 3.8 (past year)
| | | | | | | 2.8 (past 2 months)
Lagace, 1993 ^54^ | USA | 20 years & over | Cross-sectional survey with self-administered questionnaire | Urine leakage in past 12 months | 86 (men and women combined) | 104 | 11
Malmsten, 1997 ^583^ | Belgium | 45 years & over (7 birth cohorts) | Population-based with self-administered questionnaire | Urine leakage when arriving too late to the toilet, when laughing or coughing too much, continuously losing some urine, or losing some urine after micturition | 74.2 overall | 10,458 | Daily UI:
| | | | | 72.2 age 45 | | 64.1 overall
| | | | | 74.2 age 50 | | 44.0 age 45
| | | | | 74.3 age 55 | | 62.5 age 50
| | | | | 78.5 age 60 | | 52.0 age 55
| | | | | 79.6 age 65 | | 46.3 age 60
| | | | | 80.0 age 70 | | 58.1 age 65
| | | | | 77.9 age 75 | | 64.4 age 70
| | | | | 70.5 age 85–89 | | 60.0 age 75
| | | | | 69.0 age 90+ | | 58.9 age 80
| | | | | | | 71.7 ages 85–89
| | | | | | | 79.0 age 90+
| | | | | | | Weekly UI:
| | | | | | | 8.2% overall
| | | | | | | 10.0 age 45
| | | | | | | 9.4 age 50
| | | | | | | 12.0 age 55
| | | | | | | 14.6 age 60
| | | | | | | 14.0 age 65
| | | | | | | 13.3 age 70
| | | | | | | 8.0 age 75
| | | | | | | 8.9 age 80
| | | | | | | 5.2 ages 85–89
| | | | | | | 3.7 age 90+
| | | | | | | Monthly UI:
| | | | | | | 15.1 overall
| | | | | | | 30.0 age 45
| | | | | | | 12.5 age 50
| | | | | | | 24.0 age 55
| | | | | | | 17.1 age 60
| | | | | | | 18.6 age 65
| | | | | | | 13.3 age 70
| | | | | | | 18.0 age 75
| | | | | | | 23.2 age 80
| | | | | | | 10.7 ages 85–89
| | | | | | | 7.4 age 90+
Bogren, 1997 ^61^ | Sweden | 65 years & over | Population-based mailed survey | Involuntary urine loss | 92% | 233 | 29
Schulman, 1997 ^587^ | Belgium | 30 years & over | Population-based mailed survey | Urine leakage when arriving too late to the toilet, when laughing or coughing too much, continuously losing some urine, or losing some urine after micturition | 89% | 2,499 | 5.2 overall
| | | | | Men and women combined | | 0.8 30–34 years
| | | | | | | 2.6 35–39 years
| | | | | | | 2.0 40–44 years
| | | | | | | 2.3 45–49 years
| | | | | | | 4.9 50–54 years
| | | | | | | 4.9 55–59 years
| | | | | | | 5.5 60–64 years
| | | | | | | 8.5 65–69 years
| | | | | | | 13.8 70+ years
Thom, 1997 ^59^ | USA | 65 years & over | Population-based using medical record and hospital records | UI diagnosis in medical record | — | 2,982 | 5.3% all ages
| | | | | | | 2.8% 65–74 years
| | | | | | | 5.6% 75–79 years
| | | | | | | 7.6% 80+ years
Damián, 1998 ^35^ | Spain | 65 years & over | Population-based survey with in-home interview | Current involuntary urine leakage | 71.2 (men and women combined | 582 (men and women) | 35.8 (men only)
Koyama, 1998 ^63^ | Japan | 66 years & over | Population-based survey with self-administered questionnaire | Involuntary urine leakage—ever | — | 856 | 4.7%
Roe, 1999 ^594^ | UK | 18 years & over | Population-based mailed survey | Urine leakage at least twice a month | 52.4% | 2,681 | 5.3%
Bortolotti, 2000 ^72^ | Italy | 50 years & over | Population-based survey with telephone interviews and nested case-control with in-home interviews | Urine leakage in past year | | 2,721 telephone interviews | 3.4 in past year (overall)
| | | | | | 64 home interviews | 2.0 51–60 years
| | | | | | | 2.6 61–70 years
| | | | | | | 6.6 70+ years
MacLennan, 2000 ^7^ | Australia | 15–97 years | Population-based with in-home interviews | Stress or urge UI | 73.3% | 1,464 | 4.4%
Smoger, 2000 ^181^ | USA | 25–93 years | Cross-sectional survey with in-home interview | Urine loss in past 12 months | 85% | 840 | 32.3 (overall)
| | | | | | | 32 White
| | | | | | | 33.1 Black
| | | | | | | 36.4 Other
| | | | | | | 25.4 ≤40 years
| | | | | | | 30.9 41–50 years
| | | | | | | 31.4 51–60 years
| | | | | | | 36.3 61–70 years
| | | | | | | 33.2 71–80 years
| | | | | | | 20.0 >80 years
Temml, 2000 ^75^ | Austria | 20 years & over | Cross-sectional survey with self-administered questionnaire | Involuntary urine loss within past 4 weeks | Not reported | 332 | 5.0 overall
| | | | | | | 1.7 20–39 years
| | | | | | | 2.7 30–39 years
| | | | | | | 3.9 40–49 years
| | | | | | | 3.7 50–59 years
| | | | | | | 7.6 60–69 years
| | | | | | | 11.5 70+ years
Ueda, 2000 ^74^ | Japan | 40 years & over | Population-based mailed survey | Urine leakage | 52.5% (men and women combined) | 818 | 2 40–59 years
| | | | | | | 4 60–69 years
| | | | | | | 4 70 + years
Maggi, 2001 ^81^ | Italy | 65 years & over | Population-based survey with in-home interview | Involuntary urine leakage ever | 89 | 867 | 11.5 (overall)
| | | | | | | 4.6 65–69 years
| | | | | | | 12.6 70–74 years
| | | | | | | 12.3 75–79 years
| | | | | | | 22.2 80–84 years
| | | | | | | 23.6 ≥90 years
Stoddart, 2001 ^82^ | UK | 65 years & over | Population-based mailed survey | Urine leakage in past month | 79% | 781 | 23 (overall)
| | | | | | | 12 65–69 years
| | | | | | | 21 70–74 years
| | | | | | | 22 75–79 years
| | | | | | | 34 ≥80 years
Bogner, 2002 ^88^ | USA | 50–96 years | Population-based mailed survey | Losing urine or having trouble getting to bathroom in past 12 months | 95% | 279 | 10.8
Finkelstein 2002 ^86^ | Canada | 30 years & over | Population-based mailed survey | Self-report of urinary incontinence diagnosed by a health professional | 93.6% | 25,400 | 1.4 per 100 for overall (weighted estimate)
| | | | | | | 0.2 30–39 years
| | | | | | | 0.4 40–49 years
| | | | | | | 1.1 50–59 years
| | | | | | | 2.7 60–69 years
| | | | | | | 5.7 70–79 years
| | | | | | | 6.4 80+ years
Langa, 2002 ^595^ | USA | 70 years & over | Population-based survey with in-person interviews | Urine loss during past 12 months | — | 2,255 | 13%
Van Oyen, 2002 ^92^ | Belgium | 15 years & over | Population-based survey with in-home interview | Loss of occurring bladder control sometimes | 60 | 3,462 | 1.4% (weighted estimate)
| | | | | | | 0.1 % 15–24 years
| | | | | | | 0% 25–34 years
| | | | | | | 0.6% 35–44 years
| | | | | | | 0.9% 45–54 years
| | | | | | | 2.7% 55–64 years
| | | | | | | 5.2% 65–74 years
| | | | | | | 13.3% 75+ years
Araki, 2003 ^107^ | Japan | 40–92 years | Cross-sectional outpatient survey | Amount of urine leakage | 46% | 305 | 24
| | | | | Men and women combined
Boyle, 2003 ^585^ | France, Netherlands, South Korea, and UK | 40–79 years | Population-based with in-person interview | Current urine leakage | Not reported | 4,979 | 7.3% France
| | | | | | | 16.2% Netherlands
| | | | | | | 4.3% South Korea
| | | | | | | 14.4% UK
| | | | | | | By age:
| | | | | | | France:
| | | | | | | 5.2% 40–49 years,
| | | | | | | 9.2% 60–69 years
| | | | | | | Netherlands:
| | | | | | | 12.7% 40–49 years,
| | | | | | | 2.6% 60–69 years
| | | | | | | South Korea:
| | | | | | | 1.9% 40–49 years,
| | | | | | | 8.0% 60–69 years
| | | | | | | UK:
| | | | | | | 14.4% 40–49 years,
| | | | | | | 13.7% 60–69 years
Landi, 2003 ^97^ | Italy | 65 years & over | Population-based survey using Minimum Data Set for Home Care | Any involuntary urine loss regardless of amount ≥2 times/week | — | 2,178 | 49
Adelmann, 2004 ^30^ | USA | 65 years & over | Population-based survey with in-home interview | Positive response to one of 6 questions: trouble holding urine or leaking urine; losing urine when one coughs, sneezes, laughs, or with physical activity; losing urine on the way to the bathroom; frequently losing small amounts of urine; other kinds of urinary accidents; and ever having urinary accidents; or involuntary urine loss | 59% (men and women combined) | 163 | By self report:
| | | | | | | 25.8 (ever/current)
| | | | | | | 11.7 (past week)
| | | | | | | 13.6 (medically-detected)
Andersson, 2004 ^37^ | Sweden | 18–79 years | Population-based mailed survey | Any urine leakage or urine leakage at least once a week | 64.5% (men and women combined) | 7,680 surveyed; response not provided | 3% (weekly)
| | | | | | | 1% 18–34 years
| | | | | | | 2% 35–49 years
| | | | | | | 3% 50–64 years
| | | | | | | 8% 65–79 years
| | | | | | | 10% (any time)
| | | | | | | 3% 18–34 years
| | | | | | | 6% 35–49 years
| | | | | | | 13% 50–64 years
| | | | | | | 21% 65–79 years
Haltbakk, 2004 ^586^ | Norway | 39–91 years | Cross-sectional mailed survey of men with BPH diagnosis | Any involuntary urine leakage | 78% | 612 | 37
Holroyd-Leduc, 2004 ^113^ | USA | 69–103 years | Population-based survey with in-home interview | Any amount of urine loss during past 12 months | 87.4% (men and women combined) | 1,041 | 8.5
Lagergren, 2004 ^115^ | Sweden | 65 years & over | Population-based survey with self-administered questionnaires and clinic examinations | Urine loss during the past 12 months with at least one episode in past month | 50–74 depending on region | 3,053 | 8.5
Østbye, 2004 ^186^ | Canada | 65 years & over | Population-based mailed survey | Ever lose bladder control or pass water | — | 3,574 | 9% (overall)
| | | | | | | 6.3% 65–68 years
| | | | | | | 7.2% 70–74 years
| | | | | | | 9% 75–79 years
| | | | | | | 11.2% 80–84 years
| | | | | | | 16.6% 85–89 years
| | | | | | | 16.9% 90+ years
Teunissen, 2004 ^111^ ' | Netherlands | 60 years & over | Population-based mailed survey | Involuntary urine loss twice a month or more | 88 | 2,589 | 9% (overall)
| | | | | | | 5% 65–69 years
| | | | | | | 6% 65–69 years
| | | | | | | 8% 70–74 years
| | | | | | | 14% 75–79 years
| | | | | | | 21% ≥80 years
Anger, 2006 ^8^ | USA | 60 years & over | Population-based survey with in-home interview | Difficulty controlling bladder, including small amounts of urine loss with coughing or sneezing over past 12 months | NA | Not reported | 17
| | | | | | | Weighted estimates
| | | | | | | 21 (Non-Hispanic Blacks)
| | | | | | | 16 (Non-Hispanic Whites)
| | | | | | | 14% (Mexican Americans)
Irwin, 2006 ^145^ | Canada, Germany, Italy, Sweden, UK | 18 years & over | Population-based computer-assisted telephone interview | Frequency of urine leakage | 33% men and women combined | Not reported | 5.4
Lewinshtein, 2006 ^588^ | Canada | 33–80 years | Cross-sectional survey using self-administered questionnaire | Frequency of urine leakage over past 4 weeks | Not reported | 366 | 10
Mardon, 2006 ^39^ | USA | 65 years & over | Random sample of Medicare enrollees | Urine leakage in past 6 months | 67% | 88,708 | 27.9 (overall)
| | | | | (men and women combined) | | 30.6% Hispanics
| | | | | | | 37.9% Non-Hispanics
| | | | | | | 38.7% American Indians
| | | | | | | 31.6% Asians
| | | | | | | 30.3% African Americans
| | | | | | | 38.3% Whites
| | | | | | | 31.2% Other
Diokno, 2007 ^589^ | USA | 18 years & over | Population-based mailed survey | Urine leakage in past 30 days | — | 21,590 | 12.7 (overall)
| | | | | | | 7.3% 18–24 years
| | | | | | | 7.2% 35–44 years
| | | | | | | 11.0% 45–54 years
| | | | | | | 15.6% 55–64 years
| | | | | | | 23.8% 65–74 years
| | | | | | | 30.2% 75+ years

#### Prevalence, severity, and impact of UI

Prevalence estimates for the adult population are fairly consistent, with most estimating between 16 to 22 percent. ^8,^ ^9,^ ^30,^ ^35,^ ^37,^ ^38,^ ^120^ However, estimates varied according to age and gender. Adults ages 60 years and over have the highest rates of UI. Prevalence rates differ substantially by gender, with women having higher rates across all age groups. One large study of adults ages 40 and over reported a female to male ratio at 2:6. ^38^

#### Incidence of UI

The incident rate for the adult population varies by age, gender, and race. In a sample of 17,421 men and women ages 40 years and over, the 1-year incidence was 6 percent, ^38^ whereas in a study of 2,087 adults over age 70, the 2-year incidence was 20 percent, with 21 percent for urge UI and 20 percent for stress UI. ^33^ The largest survey involving 58,658 American men and women 65 years and over estimated a 2-year incidence rate of UI at 37 percent, ^39^ with rates being significantly higher in women than men, 44 and 28 percent, respectively. In this study, the incidence of UI measured as any urine loss experienced in the past 6 months increased with age beginning at 32 percent in adults 65–69 years and increasing to 54 percent in those over age 95. The impact of UI was greatest in the oldest age groups, with those rating a big impact varying from 14 percent of those 65–69 years to 27 percent for those 90–94, and 38 percent in those over 95 years. This study also found that non-Hispanics (38 percent) are more likely to be incontinent than Hispanics (31 percent), and American Indians and Whites had higher rates of UI than Blacks and Asians. ^39^ In contrast, Hispanics rated a slightly greater UI impact, e.g., a big problem (25 percent) compared to non-Hispanics (17 percent). A higher proportion of American Indians (30 percent) rated UI as having a big impact compared to Blacks (20 percent), Whites (17 percent), and Asians (15 percent). ^39^

### Progression and Remission of UI in Community Dwelling Adults

There is limited data on UI progression and remission rates comparing men and women. Evidence in adults ages 60 and over suggests that changes in severity over a 2-year period progress from continence to mild UI, and from mild to moderate UI. ^47^ Few people advanced to severe incontinence (e.g., 300 or more days of urine leakage and/or greater than a quarter cup of urine loss per day on 50 or more days during past 12 months) ^47^ One study found change patterns varied between women and men ages 60 years and over. ^47^ Women first developed stress UI and mixed UI as a primary condition, with urge UI as a secondary condition, whereas men developed urge UI, with stress UI as a potential secondary condition. Significantly more men than women developed urge UI over the 2-year followup period. Conflicting findings were noted in examining progression rates over a longer followup period. In a study of adults ages 70 and over involving a 10-year followup, women developed urge UI more frequently than men (23 versus 11 percent). ^578^

UI remission rates vary by gender, with women having more stable incontinence (e.g., lower remission rates). ^47^ At 1 year, the remission rates for women and men were 11 and 27 percent, respectively, and at 2 years, they were 13 and 32 percent, respectively. ^47^

### Prevalence of UI in Community Dwelling Women

#### Overview

We identified 117 epidemiological studies of UI prevalence in community dwelling women ^7,^ ^8,^ ^30,^ ^35^ – ^148^ that have been published over the past 17 years, with both broad and narrow age spans of women within specific countries or regions of countries. The majority of the studies have been conducted in the United States (40 studies), ^8,^ ^30,^ ^39,^ ^44,^ ^45,^ ^47,^ ^50,^ ^54^ – ^56,^ ^59,^ ^66,^ ^67,^ ^88^ – ^90,^ ^93,^ ^102,^ ^105,^ ^110,^ ^113,^ ^118,^ ^120,^ ^123,^ ^124,^ ^126,^ ^128,^ ^130,^ ^134,^ ^136^ – ^141,^ ^144,^ ^146^ – ^149^ UK (10 studies), ^36,^ ^38,^ ^43,^ ^52,^ ^70,^ ^77,^ ^82,^ ^103,^ ^112,^ ^132^ or Northern Europe, including 13 studies from Sweden, ^37,^ ^48,^ ^53,^ ^57,^ ^61,^ ^69,^ ^71,^ ^99,^ ^114,^ ^115,^ ^119,^ ^129,^ ^131^ four studies from Norway, ^49,^ ^62,^ ^80,^ ^98^ six studies from Denmark, ^51,^ ^64,^ ^73,^ ^78,^ ^96,^ ^133^ and one study from Finland. ^106^

Prevalence rates regarding these variations can be attributed to differences in study populations, survey methodology (including sampling, definition, and measurement of UI), and reporting methods (Table 1). Although most studies of women are concentrated in middle-age and older women, other studies incorporate a broader age span with samples beginning at ages 15, 18, to 20 years and over. Study designs vary from probability-based methods of sampling of either large populations or random samples drawn from general practices, insurance plan enrollees; cross-sectional analyses of prospective cohorts of women who are participants in longitudinal studies or clinical trials in which UI is not a primary aim, cross-sectional studies of clinical populations or national panels, to case-control studies examining the effect of surgical interventions such as hysterectomy. Survey methodology involves mailed questionnaires, in-home interviews by trained interviewers, computer-assisted telephone interviews, or clinical evaluations. The definition and measurement of UI vary widely; over 20 definitions have been used (Table 1). Pooled prevalence of ever having UI was increased from 21 percent in 19–44 years old (17 studies) to 34 percent in 45–64 years old (45 studies), and to 39 percent among elderly women (11 studies) (Table 2). The differences across studies can create artifacts, as seen in Table 2, where the mean pooled prevalence for “ever” is less than the monthly rate. Younger females reported UI in the past year less frequently (9.61 percent, two studies), the prevalence increased to 35 percent among women 45–64 (11 studies) and to 41 percent among those older than 65 years old (13 studies). Elderly women reported UI in the past month (four studies) more often (56.7 percent).

Table 2 Pooled prevalence of UI in women by time of occurrence (random effects model, statistical test for between studies heterogeneity significant for all estimates)

Age | Ever | | In the Past Month | | In the Past Year
| | Prevalence (95% CI) | | Prevalence (95% CI) | | Prevalence (95% CI)
19–44 | 17 studies | 21.3 | 5 studies | 25.2 | 2 studies | 13.37
| Samuelsson, 1997 ^57^ | (16.3; 26.2) | Hagglund, 1999 ^69^ | (21.7; 28.7) | Foldspant, 1999 ^64^ | (9.61; 17.13)
| Foldspang, 1999 ^64^ | US* | Temml, 2000 ^75^ | US* | Chiarelli, 1999 ^68^
| Hannestad, 2000 ^80^ | 28 (27.8; 28.) | Peyrat, 2002 ^85^ | 30 (0; 59)
| Peyrat, 2002 ^85^ | | Miller, 2003 ^100^
| Van der Vaart, 2002 ^91^ | | Nygaard, 2005 ^130^
| Van Oyen, 2002 ^92^
| Chen, 2003 ^95^
| Rortveit, 2003 ^98^
| Chen, 2003 ^101^
| Miller, 2003 ^104^
| Parazzini, 2003 ^108^
| Mawajdeh, 2003 ^109^
| Andersson, 2004 ^37^
| Schytt, 2004 ^119^
| Nygaard, 2005 ^130^
| Rohr, 2005 ^133^
| Irwin, 2006 ^145^
| Melville, 2005 ^124^ *
45–64 | 45 studies | 34.1 | 7 studies | 40.1 | 11 studies | 35.4
| Rekers, 1992 ^41^ | (29.6; 38.5) | Hagglund, 1999 ^69^ | (36.7; 43.5) | Mommsen, 1994 ^51^ | (31.6; 39.2)
| Burgio, 1001 ^44^ * | US* | Temml, 2000 ^75^ | US* | Lagace, 1993 ^54^ * | US*
| Seim, 1995 ^49^ | 43.2 | Swithinbank, 1999 ^77^ | 44.3 | Foldspang, 1999 ^64^ | 37.6
| Mommsen, 1994 ^51^ | (37.1; 49.3) | Schmidbauer, 2001 ^83^ | (31.7; 56.7) | Chiarelli, 1999 ^68^ | (33.3; 41.9)
| Brocklehurst, 1993 ^52^ | | Peyrat, 2002 ^85^ | | Kuh, 1999 ^70^
| Samuelsson, 1997 ^57^ | | Miller, 2003 ^100^ | | Bortolotti, 2000 ^72^
| Bogren, 1997 ^61^ | | Hunskaar, 2004 ^112^ | | MacLennan, 2000 ^7^
| Dolan, 1999 ^65^ | | | | Sampselle, 2002 ^93^ *
| Kuh, 1999 ^70^ | | | | Grodstein, 2003 ^105^ *
| Moller, 2000 ^73^ | | | | Danforth, 2006 ^138^ *
| Ueda, 2000 ^74^ | | | | Waetjen, 2007 ^149^ *
| Temml, 2000 ^75^
| Swithinbank, 1999 ^77^
| Alling Moller, 2000 ^78^
| Hannestad, 2000 ^80^
| Muscatello, 2001 ^84^
| Peyrat, 2002 ^85^
| Van der Vaart, 2002 ^87^
| Sze, 2002 ^89^ *
| Van Oyen, 2002 ^92^
| Chen, 2003 ^95^
| Stewart, 2003 ^102^ *
| Miller, 2003 ^104^
| Parazzini, 2003 ^108^
| Hunskaar, 2004 ^112^
| McGrother, 2004 ^38^
| Andersson, 2004 ^37^
| Ozerdogan, 2004 ^116^
| Corcos, 2004 ^117^
| Vandoninck, 2004 ^122^
| Melville, 2005 ^124^ *
| Ruff, 2005 ^126^ *
| Kocak, 2005 ^127^
| Tegerstedt, 2005 ^129^
| Teleman, 2005 ^131^
| Fritel, 2005 ^135^
| Goldberg, 2005 ^136^ *
| Thom, 2006 ^137^ *
| Wehrberger, 2006 ^139^ *
| Lukacz, 2006 ^141^ *
| Swanson, 2005 ^143^
| Irwin, 2006 ^145^
| Waetjen, 2007 ^149^ *
| Kinchen, 2007 ^148^ *
65+ | 40 studies | 35.1 | 9 studies | 44.2 | 13 studies | 40.8
| Molander, 1990 ^48^ | (33.9; 36.2) | Hagglund, 1999 ^69^ | (38.9; 49.4) | Herzog, 1990 ^47^ * | (32.7; 48.9)
| Wetle, 1995 ^50^ * | US* | Temml, 2000 ^75^ | US* | Thom, 1997 ^59^ * | US*
| Milsom, 1993 ^53^ | 35.8 | Swithinbank, 1999 ^77^ | 47.7 | Chiarelli, 1999 ^68^ | 47
| Nygaard, 1996 ^56^ | (30.7; 40.9) | Stoddart, 2001 ^82^ | (38.9; 56.3) | Bortolotti, 2000 ^72^ | (38.9; 55.1)
| Nakanishi, 1997 ^58^ | | Muscatello, 2001 ^84^ | | Bogner, 2002 ^88^ *
| Thom, 1997 ^59^ * | | Peyrat, 2002 ^85^ | | Espino, 2003 ^110^ *
| Bogren, 1997 ^61^ | | Miller, 2003 ^100^ | | Lagergren, 2004 ^115^
| Koyama, 1998 ^63^ | | Bradley, 2005 ^125^ * | | Jackson, 2004 ^118^ *
| Damian, 1998 ^35^ | | Jackson, 2005 ^128^ * | | Jackson, 2004 ^123^ *
| Brown, 1999 ^66^ * | | | | Mardon, 2006 ^39^ *
| Stenberg, 1999 ^71^ | | | | Brown, 2006 ^140^ *
| Bortolotti, 2000 ^72^ | | | | Jackson, 2006 ^144^ *
| Ueda, 2000 ^74^ | | | | Huang, 2007 ^147^ *
| Gavira Iglesias, 2000 ^76^
| Hannestad, 2000 ^80^
| Maggi, 2001 ^81^
| Muscatello, 2001 ^84^
| Peyrat, 2002 ^85^
| Buchsbaum, 2002 ^90^ *
| Van Oyen, 2002 ^92^
| Dallosso, 2003 ^103^
| Miller, 2003 ^104^
| Nuotio, 2003 ^106^
| Araki, 2003 ^107^
| Parazzini, 2003 ^108^
| Espino, 2003 ^110^ *
| McGrother, 2004 ^38^
| Andersson, 2004 ^37^
| Adelmann, 2004 ^30^ *
| Bogner, 2004 ^120^ *
| Oskay, 2005 ^121^
| Jackson, 2004 ^123^ *
| Bradley, 2005 ^125^ *
| Jackson, 2005 ^128^ *
| McGrother, 2006 ^132^
| Rohr, 2005 ^133^
| Tannenbaum, 2006 ^142^
| Swanson, 2005 ^143^
| Irwin, 2006 ^145^
| Anger, 2006 ^2^ *
80+ | 11 studies | 38.5 | 4 studies | 56.7 | 4 studies | 22.9
| Stenberg, 1999 ^71^ | (36.1; 40.9) | Nuotio, 2003 ^106^ | (50.3; 63.1) | Brown, 1996 ^55^ * | (12.5; 33.3)
| Ueda, 2000 ^74^ | US* | Stoddart, 2001 ^82^ | | Fultz, 1999 ^67^ * | US*
| Hannestad, 2000 ^80^ | 50.8 | Stenzelius, 2004 ^114^ | | Bortolotti, 2000 ^72^ | 24.6
| Maggi, 2001 ^81^ | (35.7; 65.9) | Temml, 2000 ^75^ | | Holroyd-Leduc, 2004 ^113^ * | (12.4; 36.7)
| Muscatello, 2001 ^84^
| Van Oyen, 2002 ^92^
| Nuotio, 2003 ^106^
| McGrother, 2004 ^38^
| Adelmann, 2004 ^30^ *
| Rohr, 2005 ^133^
| Swanson, 2005 ^143^

* Studies conducted in the U.S.

#### Prevalence, severity, and impact of UI

were reported using standardized scales or instruments. Following the method used by the 3^rd^ International Consultation on Incontinence in summarizing prevalence estimates in women, ^579^ the authors used the most inclusive definition of UI (“monthly UI,” “weekly UI,” and “daily UI”). Severity was measured by volume of urine lost, by categorical rating scale of the individual's perception, or by seeking professional help. The amount of urine lost was typically categorized as “drops” to “wets outer clothing” or “runs down the legs/floor.” In some studies, a higher percentage of women tended to lose drops ^45,^ ^121,^ ^122^ in comparison to larger volumes, whereas in other studies, women were more likely to have damp underwear and/or wet underwear or clothing than losing drops. ^128^ The severity of the leakage has been shown to vary by the frequency of leakage, with infrequent leakage more likely to be associated with drops, whereas daily leakage with a greater number having to change undergarments or outergarments. ^45^ There are conflicting findings about whether younger or older populations rate their UI as more severe. ^38,^ ^130^ In one study, older women tended to rate their UI as more severe than much younger women. ^38^ In a few studies, severity was measured by the perception of how severe a problem UI is to how much daily life is restricted. ^37,^ ^55,^ ^190,^ ^580^

Differences in reporting prevalence rates in UI types make comparisons challenging across studies, as some studies report frequencies within the incontinent group and others report the rates within the overall population (Table 3). Overall prevalence of monthly UI was the highest in elderly females (25.3 percent, 95 percent CI 14.1; 36.5) (two studies) ^111,^ ^133^ and in women 45–64 years old (20.5 percent, 95 percent CI 18.3; 22.8) (9 studies). ^43,^ ^45,^ ^46,^ ^62,^ ^116,^ ^124,^ ^132,^ ^133,^ ^148^ Weekly incontinence was experienced more often by women older than 65 years (16.9 percent, 95 percent CI 15.1; 18.8) ^42,^ ^94,^ ^97,^ ^148^ and elderly women over 80 (29.9 percent, 95 percent CI 25.4; 34.4). ^42^ Few studies reported daily UI, 5 percent of younger women (19–44 years old) ^96^ and 17 percent of women older than 65 years ^79^ reported having daily leakage. Severe UI, defined as wet clothes or severe enough to seek treatment, was experienced by 9 percent of women over 65 (8.96 percent, 95 percent CI 7.51; 6), ^59,^ ^76,^ ^77,^ ^86,^ ^128,^ ^144^ and 10 percent of middle-aged women (95 percent CI 9.37;11) (seven studies). ^40,^ ^51,^ ^60,^ ^77,^ ^86,^ ^89,^ ^131^ Less than 2 percent of women younger than 45 years old experienced severe UI. ^86^

Table 3 Pooled prevalence of UI in women by frequency and severity (random effects model, statistical test for between studies heterogeneity significant for all estimates)

Age | Monthly | | Weekly | | Daily | | Severe
| | Prevalence (95% CI) | | Prevalence (95% CI) | | Prevalence (95% CI) | | Prevalence (95% CI)
19–44 | | | 3 studies | 7.4 | 1 study | 5.1 | 1 study | 1.5
| | | Kinchen, 2007 ^148^ * | (0.9; 13.9) | Hvidman, 2003 ^96^ | (1.4; 8.9) | Finkelstein, 2002 ^86^ | (0.8; 2.1)
| | | Rohr, 2005 ^133^ | US* 10.3 | | US*
| | | Eva, 2003 ^99^ | (0; 25.2) | | 3.7
| | | | | | (0.1; 7.41)
45–64 | 9 studies | 20.6 | 6 studies | 16 | 9 studies | 8.1 | 7 studies | 10.2
| O'Brien, 1991 ^43^ | (18.3; 22.8) | Rekers, 1992 ^41^ | (13.3; 18.7) | Burgio, 1991 ^45^ * | (6.3; 10) | Rekers, 1992 ^40^ | (9.4; 11)
| Burgio, 1991 ^45^ * | US* | Roe, 2000 ^36^ | US* | Goldberg, 2005 ^136^ * | US* | Mommsen, 1994 ^51^ | US*
| Rekers, 1992 ^46^ | 21.9 | Eva, 2003 ^99^ | 17.3 | Hannestad, 2000 ^80^ | 8.9 | Brieger, 1997 ^60^ | 10.5
| Holtedahl, 1998 ^62^ | (19.1; 24.9) | Lifford, 2005 ^134^ * | (14.2; 20.4) | Kinchen, 2007 ^148^ * | (5.5; 12.4)) | Swithinbank, 1999 ^77^ | (9.1; 11.8)
| Ozerdogan, 2004 ^116^ | | Harris, 2007 ^146^ * | | Lagace, 1993 ^54^ | | Finkelstein, 2002 ^86^
| Melville, 2005 ^124^ * | | Kinchen, 2007 ^148^ * | | Ruff, 2005 ^126^ | | Sze, 2002 ^89^ *
| McGrother, 2006 ^132^ | | | | Samuelsson, 1997 ^57^ | | Teleman, 2005 ^131^
| Rohr, 2005 ^133^ | | | | Vandoninck, 2004 ^122^
| Kinchen, 2007 ^148^ * | | | | Thom, 1997 ^59^ *
65+ | 4 studies | 22.7 | 4 studies | 16.9 | 10 studies | 17 | 5 studies | 8.9
| O'Brien, 1991 ^43^ | (20.9; 24.5) | Kok, 1992 ^42^ | (15.1; 18.8) | Tseng, 2000 ^79^ | (13.2; 21) | Thom, 1997 ^59^ * | (7.5; 0.4)
| Holtedahl, 1998 ^62^ | US* | Landi, 2002 ^94^ | US* | Espino, 2003 ^110^ * | US* | Gavira-Iglesias, 2000 ^76^ | US*
| Teunissen, 2004 ^111^ | 17.5 | Landi, 2003 ^97^ | 11.3 | Anger, 2006 ^2^ * | 8.3 | Swithinbank, 1999 ^77^ | 8
| Rohr, 2005 ^133^ | (12.3; 22.7) | Kinchen, 2007 ^148^ * | (9.1; 13.5) | Bradley, 2005 ^125^ * | (6.2; 10.5) | Finkelstein, 2002 ^86^ | (7.2; 8.8)
| | | | | Huang, 2007 ^147^ * | | Jackson, 2005 ^128^ *
| | | | | Jackson, 2005 ^128^ * | | Jackson, 2006 ^144^ *
| | | | | Kinchen, 2007 ^148^ *
| | | | | Oskay, 2005 ^121^
| | | | | Stoddart, 2001 ^82^
| | | | | Thom, 1997 ^59^ *
80+ | 2 studies | 25.3 | 1 study | 29.9 | 2 studies | 38 | 1 study | 15.5
| Rohr, 2005 ^133^ | (14.1; 36.6) | Kok, 1992 ^42^ | (25.4; 34.5) | Anger, 2006 ^2^ * | (32.4; 44 | Finkelstein, 2002 ^86^ | (10.7; 20.3)
| Teunissen, 2004 ^111^ | | | | Brown, 1999 ^66^ *

* Studies conducted in the U.S.

#### Racial/ethnic differences

The majority of epidemiological studies have been conducted in White women in North America, Europe, Australia, and New Zealand. Although several studies have been conducted in Asian countries, including Turkey, ^58,^ ^60,^ ^79,^ ^95,^ ^116,^ ^121^ because of methodological differences, it is difficult to directly compare those to studies in which varying racial/ethnic groups have been sampled. There have been a limited number of studies from Middle Eastern countries, with only one study from an African country.

Eight population-based studies in the United States have reported on racial/ethnic differences in the prevalence of UI in women (Table 1). The majority of these studies document a higher prevalence of UI (including all types) in White women as compared to Black, Hispanic, and Asian women.

#### Type of UI

In general, stress and mixed UI were the most common types in studies that have compared stress, urge, and mixed UI (16 out of 28 studies) (Table 4). Although surveys have found differences in the frequencies of the different types of UI by age and race, these differences are inconsistent across studies. Some surveys found higher rates of stress UI in young and middle-aged women, ^57,^ ^74,^ ^80,^ ^104,^ ^108^ whereas others have found higher rates in older women. ^37,^ ^85,^ ^133,^ ^145,^ ^581^ Similar inconsistencies are noted with urge UI, with some studies reporting higher rates in older women ^37,^ ^106,^ ^145^ and others reporting it is more prevalent in middle-aged women ^108,^ ^133^ (Table 5). The prevalence of total UI increase in age categories from 19 percent in women 19–44 years (18 studies) ^57,^ ^64,^ ^68,^ ^69,^ ^75,^ ^80,^ ^85,^ ^86,^ ^92,^ ^96,^ ^98^ – ^100,^ ^119,^ ^130,^ ^133,^ ^145,^ ^148^ to 29 percent in those older than 45 years. Stress incontinence was the most prevalent type in women 19–44 years old (12.8 percent, 95 percent CI 8.3; 17.4) (15 studies), ^37,^ ^57,^ ^64,^ ^80,^ ^85,^ ^91,^ ^95,^ ^98,^ ^104,^ ^108,^ ^109,^ ^130,^ ^133,^ ^145,^ ^124^ and in those 45–64 years of age (21.5 percent, 95 percent CI 18.9; 24.1) (36 studies). ^37,^ ^38,^ ^44,^ ^51,^ ^57,^ ^61,^ ^70,^ ^73^ – ^75,^ ^77,^ ^78,^ ^80,^ ^84,^ ^85,^ ^87,^ ^89,^ ^95,^ ^104,^ ^108,^ ^116,^ ^117,^ ^122,^ ^124,^ ^127,^ ^129,^ ^131,^ ^135^ – ^137,^ ^139,^ ^141,^ ^145,^ ^148,^ ^149^ However, mixed UI was the most prevalent type of incontinence in older women, 16.8 percent of women older than 65 (95 percent CI 13.7; 19.9) (19 studies) ^30,^ ^35,^ ^59,^ ^66,^ ^71,^ ^72,^ ^74,^ ^80,^ ^85,^ ^90,^ ^104,^ ^106,^ ^108,^ ^110,^ ^121,^ ^128,^ ^142,^ ^143,^ ^145^ and 16 percent of elderly women (95percent CI 7.3; 24.4) reported mixed UI (seven studies). ^71,^ ^74,^ ^80,^ ^84,^ ^106,^ ^124,^ ^133^ Prevalence of urge incontinence gradually increased from 5 percent in younger women (4.9 percent, 95 percent CI 3.7; 6.1) ^37,^ ^57,^ ^64,^ ^80,^ ^85,^ ^91,^ ^95,^ ^98,^ ^101,^ ^104,^ ^108,^ ^130,^ ^133,^ ^145^ to 10 percent in women 45–64 (10.2 percent, 95 percent CI 8.9; 11.5) (32 studies), ^37,^ ^44,^ ^51,^ ^57,^ ^61,^ ^70,^ ^73^ – ^75,^ ^77,^ ^78,^ ^80,^ ^84,^ ^85,^ ^87,^ ^89,^ ^95,^ ^102,^ ^104,^ ^108,^ ^116,^ ^117,^ ^124,^ ^126,^ ^127,^ ^129,^ ^131,^ ^137,^ ^139,^ ^145,^ ^148,^ ^149^ and to 12 percent in women older than 65 years (12.2 percent, 95 percent CI 9.9; 14.5) (28 studies). ^30,^ ^35,^ ^37,^ ^56,^ ^59,^ ^61,^ ^63,^ ^66,^ ^71,^ ^72,^ ^74,^ ^80,^ ^84,^ ^85,^ ^90,^ ^104,^ ^106,^ ^108,^ ^110,^ ^118,^ ^121,^ ^123,^ ^125,^ ^128,^ ^133,^ ^142,^ ^143,^ ^145^

Table 4 Prevalence of UI by incontinence type, age, and race in community dwelling women

Author | Country | Age | Number | Stress Incontinence (%) | Urge Incontinence (%) | Mixed Incontinence (%) | Other or Unclassified Incontinence (%)
Prevalence of UI Type in Women
Burgio, 1991 ^44^ | USA | 42–50 years | 541 | 47.9 | 11.7 | 35.8
Mommsen, 1994 ^51^ | Denmark | 30–59 years | 2,589 | 14.8 | 8.6 | 7.1
Nygaard, 1996 ^56^ | USA | 65 years & over | 2,025 | 40.3 | 36.3
Bogren, 1997 ^61^ | Sweden | 65 years & over | 225 | 33 | 66
Brieger, 1997 ^60^ | Hong Kong | Mean age 45 (SD 15) | 1,054 | 10 | 0.7
Samuelsson, 1997 ^57^ | Sweden | 20–59 years | 491 | 15.7% overall | 2.0% overall | 5.3% overall | 4.7% overall
| | | | 2.0% 20–29 years | 2.5% 20–29 years | 1.3% 20–29 years | 3.5% 20–29 years
| | | | 17.0% 30–39 years | 0% 30–39 years | 2.5% 30–39 years | 4.2% 30–39 years
| | | | 28.7% 40–49 years | 3.8% 40–49 years | 4.6% 40–49 years | 4.6% 40–49 years
| | | | 21.8% 50–59 years | 2.0% 50–59 years | 12.8% 50–59 years | 6.8% 50–59 years
Schulman, 1997 ^587^ | Belgium | 30 years & over | 2,770 | 53 | 55
Thom, 1997 ^59^ | USA | 60 years & over | 939 | 16.9 | 23.9 | 23.6 | 8.3
Damián, 1998 ^35^ | Spain | 65 years & over | 589 women and women; women not reported separately | 13.5 | 12.3 | 61.8 | 12.3
Koyama, 1998 ^63^ | Japan | 66 years & over | 1,448 | 50.4 | 46.5
Brown, 1999 ^66^ | USA | Mean age 67 | 2,763 | 12.8 | 14.4 | 14.4
| | (SD 7) | | | | 10.2 (stress-mixed)
| | | | | | 5.9 (urge-mixed)
Foldspang, 1999 ^64^ | Denmark | 20–59 years | 4,710 | 15.1 | 8.7 | 6.8
Kuh, 1999 ^70^ | UK | 48 years | 1,378 | 50 | 22 | 20
Muscatello, 1999 ^84^ | Australia | 41 years & over | 262 | 35 all ages | 29 all ages
| | | | 29 41–49 years | 18 41–49 years
| | | | 42 50–59 years | 33 50–59 years
| | | | 46 60–69 years | 38 60–69 years
| | | | 27 70+ years | 32 70+ years
Stenberg, 1999 ^71^ | Sweden | 71 and 81 years | 2,245 | 36 (71 years) | 30 (71 years) | 20 (overall)
| | | | 32 (81 (years) | 31 (81 years)
Swinthinbank, 1999 ^77^ | UK | 19 years & over | 2,075 | 60 | 46 | | 6 nocturnal UI
| | | | | | | 12 unknown cause
Bortolotti, 2000 ^72^ | Italy | 50 years & over | 229 | 55 | 12 | 24
Hannestad, 2000 ^80^ | Norway | 20 years & over | 27,936 | 50 all ages | 11 all ages | 36 all ages | 3 all ages
| | | | 48 20–24 years | 13 20–24 years | 33 20–24 years | 6 20–24 years
| | | | 54 25–29 years | 13 25–29 years | 28 25–29 years | 5 25–29 years
| | | | 59 30–34 years | 10 30–34 years | 27 30–34 years | 4 30–34 years
| | | | 60 35–39 years | 7 35–39 years | 29 35–39 years | 4 35–39 years
| | | | 60 40–44 years | 8 40–44 years | 29 40–44 years | 3 40–44 years
| | | | 65 45–49 years | 7 45–49 years | 27 45–49 years | 2 45–49 years
| | | | 55 50–54 years | 7 50–54 years | 36 50–54 years | 2 50–54 years
| | | | 52 55–59 years | 9 55–59 years | 37 55–59 years | 2 55–59 years
| | | | 42 60–64 years | 10 60–64 years | 46 60–64 years | 2 60–64 years
| | | | 38 65–69 years | 16 65–69 years | 44 65–69 years | 2 65–69 years
| | | | 33 70–74 years | 16 70–74 years | 48 70–74 years | 2 70–74 years
| | | | 34 75–79 years | 19 75–79 years | 44 75–79 years | 3 75–79 years
| | | | 32 80–84 years | 21 80–84 years | 40 80–84 years | 7 80–84 years
| | | | 28 85–89 years | 23 85–89 years | 40 85–89 years | 9 85–89 years
| | | | 28 90+ years | 12 90+ years | 48 90+ years | 12 90+ years
Møller, 2000 ^73^ | Denmark | 40–60 years | 2,284 | 13.1 | 7.3 | 16.4
Temml, 2000 ^75^ | Austria | 20 years & over | 332 | 39.8 | 26.5
Ueda, 2000 ^74^ | Japan | 40–75 years | 818 | 33.9 all ages | 6.9 all ages | 12.9 all ages
| | | | 11.3 40–49 years | 1.3 40–49 years | 3.8 40–49 years
| | | | 10.6 50–59 years | 1.2 50–59 years | 4.1 50–59 years
| | | | 8.6 60–69 years | 2.6 60–69 years | 1.9 60–69 years
| | | | 3.4 70+ years | 1.8 70+ years | 3.1 70+ years
Muscatello, 2001 ^84^ | Australia | 41 years & over | 232 | 35% overall | 29% overall
| | | | 29% 41–49 years | 18% 41–49 years
| | | | 42% 50–59 years | 33% 50–59 years
| | | | 46% 60–69 years | 38% 60–69 years
| | | | 27% 70+ years | 32% 70+ years
Buchsbaum, 2002 ^90^ | USA | 39–91 years | 149 | 29.7 | 24.3 | 35.1 | 10.8
| | (mean 68 years)
Nuotio, 2002 ^106^ | Finland | 70 years & over | 227 | | All ages: 41.8
| | | | | 70–79 years: 31.2
| | | | | 80–98 years: 45.6
Peyrat, 2002 ^85^ | France | 20–62 years | 1,700 | 12.4: all ages | 1.6: all ages | 13.5: All ages
| | | | 3.0: <25 years | 0: <25 years | 3.0: <25 years
| | | | 8.3: 25–39 years | 8.3: 25–39 years | 8.5: 25–39 years
| | | | 17.3: 40–55 years | 17.3: 40–55 years | 19.0: 40–55 years
| | | | 24.0 >55 years | 0: >55 years | 24.0: >55 years
Sze, 2002 ^89^ | USA | 15–91 years | 2,370 | 39 White | 19 White
| | | | 27 Black | 16 Black
| | | | 24 Hispanic | 16 Hispanic
Van der Vaart, 2002 ^87^ | Netherlands | 35–70 years | 1,625 | 50.5 nonhysterectomy | 22.6 nonhysterectomy
| | | | 57.0 hysterectomy | 38.3 hysterectomy
Van der Vaart, 2002 ^91^ | Netherlands | 20–45 years | 1,393 | 39.1 | 15.3
Chen, 2003 ^95^ | Taiwan | 20 years & over | 1,247 | 18.0 | 18.6 | 17.1
Dallosso, 2003 ^103^ | UK | 40 years & over | 7,046 | 17.3
Espino, 2003 ^110^ | USA | 65 years & over | 1,589 | 10 | 33 | 42
| | (Mexican Americans only)
Miller, 2003 ^104^ | Australia | Three age cohorts (21–26 years; 48–53 years, and 73–79 years) | 933 | 10.7%: 21–26 years | 2.7%: 21–26 years | 86.6%: 21–26 years
| | | | 6.4%: 48–53 years | 6.4%: 48–53 years | 92.3%: 48–53 years
| | | | 2.0%: 73–79 years | 2.0%: 73–79 years | 91.1%: 73–79 years
Nuotio, 2003 ^106^ | Finland | 60–99 years | 227 | 23 | 6 | 30
Parazzini, 2003 ^108^ | Italy | 40 years & over | 2,2 | 24.3%: overall | 18.4%: overall | 45.8%: overall
| | | | 40.7%: ≤52 years | 35.4%: ≤52 years | 30.9%: ≤52 years
| | | | 36.4%: 53–61 years | 30.8%: 53–61 years | 29.4%: 53–61 years
| | | | 22.9%: ≥62 years | 33.9%: ≥62 years | 39.7%: ≥62 years
Rortveit, 2003 ^98^ | Norway | 20–64 years | 15,307 | 12.2 | 1.8 | 5.9
Stewart, 2003 ^102^ | USA | 18 years & over | 2,735 | | 9.3
Adelmann, 2004 ^30^ | USA | 65 years & over | 163 | 38.9 | 9.3 | 11.1 | 5.6
Andersson, 2004 ^37^ | Sweden | 18–79 years | — | 77% of those incontinent | 46% of those incontinent
| | | | 59% 18–34 years | 42% 18–34 years
| | | | 83% 35–49 years | 38% 35–49 years
| | | | 83% 50–64 years | 48% 50–64 years
| | | | 71% 65–79 years | 53% 65–79 years
Corcos, 2004 ^117^ | Canada | 35 years & over | 1,683 | 10.6% | 5.5%
McGrother, 2004 ^38^ | UK | 40 years & over | 5,816 | All ages: 17.3%
| | | | 16.7% 40–49 years
| | | | 19.8% 50–59 years
| | | | 16.2% 60–69 years
| | | | 15.2% 70–79 years
| | | | 18.1% ≥80 years
Jackson, 2004 ^123^ | USA | 70–79 years | 1,584 | 40% overall | 42% overall | | 14% Other
| | | | 73% Whites | 64% Whites | | 3% Not specified
| | | | 27% Blacks | 36% Blacks
Jackson, 2005 ^128^ | USA | 55–75 years | 1,107 | 17 | 10 | 32
Ozerdogan, 2004 ^116^ | Turkey | 20 years & over | 625 | 42.9 | 27.3 | 29.8
Vandoninck, 2004 ^122^ | Netherlands | 29–79 years | 1,071 | 68.9
Bradley, 2005 ^125^ | USA | 57–84 years | 297 | 51.2 | 49.2
Fritel, 2005 ^135^ | France | 49–61 years | 2,625 | 68.4
Goldberg, 2005 ^136^ | USA | 15–85 years | 542 | 51.8% overall
| | | | 43% premenopausal
| | | | 63% postmenopausal
Kocak, 2005 ^127^ | Turkey | 18 years & over | 1,017 | 33.1 | 25.6 | 41.3
Melville, 2005 ^124^ | USA | 30–90 years | 3,536 | 33 | 13 | 50
Nygaard, 2005 ^130^ | USA | 18–60 years | 3,562 | 46.5 | 9.7 | 41.9
Oskay, 2005 ^121^ | Turkey | 50 years & over | 500 | 37.2 | 32.3 | 30.5
Rohr, 2005 ^133^ | Denmark | 45 years & over | 5,795 | 24.5%: overall | 19.6% overall
| | | | 15.5%: <60 years | 9.1%: <60 years
| | | | 21.8%: 60–80 years | 16.4%: 60–80 years
| | | | 32.4%: ≥80 years | 8.0%: ≥80 years
Ruff, 2005 ^126^ | USA | 19–82 years | 233 | 76% Black | 84% Black | 68% Black
Swanson, 2005 ^143^ | Canada | 45 years & over | 606 | 17.5 | 7.4 | 26.4
Tegerstedt, 2005 ^129^ | Sweden | 30–79 years | 5,489 | 63.2 | 50.5 | 3.2
Teleman, 2005 ^131^ | Sweden | 55–64 years | 2,682 | 63 | 57.6 | | 8 nocturnal UI
| | | | | | | 20.7 unknown cause
Wehrsberger, 2006 ^139^ | Austria | 20–84 years | 441 | 34 | 13 | 53
Altman, 2006 ^597^ | Sweden | 32–90 years | 48 cases | 17% abdominal rectal prolapse surgery patients | 15% abdominal rectal prolapse surgery patients
| | | 165 controls | 16% controls | 10% controls
Brown, 2006 ^140^ | USA | 20 years & over | 1,461 | 14.4% controls | 7.7% controls
| | | | 31.2% prediabetic | 24.6% prediabetic
| | | | 30.2% diabetic | 26.4% diabetic
Irwin, 2006 ^145^ | Canada, Germany, Italy, Sweden, UK | 18 years & over | 1,675 | 48.9% of incontinent women | 1.5%: overall | 2.4%: overall | 2.8%: overall
| | | | 6.4%: overall | 1.0%: ≤ 39 years | 1.0%: ≤ 39 years | 1.7%: ≤39 years
| | | | 3.7%: ≤39 years | 1.1%: 40–49 years | 2.4%: 40–49 years | 2.3%: 40–49 years
| | | | 7.9%: 40–49 years | 2.5%: ≥ 60 years | 4.1%: ≥ 60 years | 4.6%: ≥60 years
| | | | 8.0% ≥60 years
Lukacz., 2006 ^141^ | USA | 25–89 years | 4,103 | 15% overall
| | | 787 nulliparous | 8% nulliparous
| | | 389 Cesarean delivery | 11% Cesarean delivery
| | | 2,927 vaginally parous | 18% vaginally parous
McGrother, 2006 ^132^ | UK | 40 years & over | 12,570 | 6.7
Tannebaum, 2006 ^142^ | Canada | 55 years & over | 2,361 | 32.0 | 22.0 | 35.0
Thom, 2006 ^137^ | USA | 40–69 years | 2,109 | 7.2% White | 4.8% White | Predominantly UUI
| | | | 9.0% Hispanic | 4.2% Hispanic | 4.0% White
| | | | 2.3% Black | 6.0% Black | 5.8% Hispanic
| | | | 2.4% Asian | 3.0% Asian | 7.6% Black
| | | | | | 4.4% Asian
| | | | | | Equal SUI and UUI
| | | | | | 3.3% White
| | | | | | 5.3% Hispanic
| | | | | | 1.9% Black
| | | | | | 3.2% Asian
Kinchen, 2007 ^148^ | USA | 21–75 years | 3,344 | 42.5 | 12.7 | 43.4
Waetjen, 2007 ^149^ | USA | 40–55 years | 3,302 | 15.9% Overall | 7.6% Overall | 12.4% Overall | 1.6% Overall
| | | | 31.8% Whites | 7.7% Whites | 15.5% Whites | 2.1% Whites
| | | | 13.1% Blacks | 11.8% Blacks | 12.9% Blacks | 1.7% Blacks
| | | | 23.3% Chinese | 3.2% Chinese | 7.2% Chinese | 1.2% Chinese
| | | | 31.1% Japanese | 3.8% Japanese | 6.8% Japanese | 1.1% Japanese
| | | | 21.2% Hispanic | 1.4% Hispanic | 4.8% Hispanic | 0% Hispanic
Prevalence of UI Type in Men
Bogren, 1997 ^61^ | Sweden | 65 years & over | 233 | 10
Mozes 1997 ^598^ | Israel | 45–75 years | 896 | 2.1
Schulman, 1997 ^587^ | Belgium | 30 years & over | 2,499 | | 45
Damián 1998 ^35^ | Spain | 65 years & over | 589 men and women; men not reported separately | | 52.2 | 16.1 | 21.1
Koskimaki, 1998 ^584^ | Finland | 50, 60, and 70 years | 2,128 | 9 | 17
Koyama, 1998 ^63^ | Japan | 66 years & over | 856 | 11.4 | 54.3
Temml, 2000 ^75^ | Austria | 20–96 years | 1,236 | 5.9 | 26.5 | | 15.3 nocturnal UI
Muscatello, 2001 ^84^ | Australia | 41 years & over | 232 | 9% overall | 9% overall
| | | | 7% 41–49 years | 7% 41–49 years
| | | | 2% 50–59 years | 2% 50–59 years
| | | | 25% 60–69 years | 18% 60–69 years
| | | | 9% 70+ years | 17% 70+ years
Ueda, 2000 ^74^ | Japan | 40–75 years | 1,836 | 1.3% overall | 7.7% overall | 1.5% overall
| | | | 0.2% 40–49 years | 0.9% 40–49 years | 0% 40–49 years
| | | | 0.5% 50–59 years | 0.7% 50–59 years | 0.4% 50–59 years
| | | | 0.5% 60–69 years | 2.7% 60–69 years | 0.7% 60–69 years
| | | | 0.1% 70+ years | 3.4% 70+ years | 0.4% 70+ years
Engstrom, 2003 ^599^ | Sweden | 40 years & over | 2,217 | 2% overall
| | | | 1% 40–49 years
| | | | 2% 50–59 years
| | | | 4% 60–69 years
| | | | 5% 70–80 years
Nuotio, 2003 ^106^ | Finland | 70 years & over | 171 | 23 | 6 | 30
Stewart, 2003 ^102^ | USA | 18 years & over | 2,469 | | 2.6
Andersson, 2004 ^37^ | Sweden | 18–79 years | | 13% overall | 45% overall
| | | | 18% 18–34 years | 18% 18–34 years
| | | | 13% 35–49 years | 37% 35–49 years
| | | | 11% 50–64 years | 43% 50–64 years
| | | | 13% 65–79 years | 59% 65–79 years
Corcos, 2004 ^117^ | Canada | 35 years & over | 1,566 | 10.6 | 5.5
Irwin, 2006 ^145^ | Canada, German, Italy, Sweden, UK | 18 years & over | 19,165 | 0.6% overall | 1.2% overall | 0.6% overall | 2.9% overall
| | | (both genders) | 0.1% ≤39 years | 0.4% ≤39 years | 0.4% ≤39 years | 1.5% ≤39 years
| | | | 0.6% 40–59 years | 1.3%: 40–59 years | 0.4%: 40–59 years | 3.0%: 40–59 years
| | | | 1.6%: ≥60 years | 2.5%: ≥60 years | 1.2%: ≥60 years | 5.2%: ≥60 years
Diokno, 2007 ^589^ | USA | 18 years & over | 21,590 | 24.5% overall | 44.6% overall | 18.8% overall | 12.3% overall
| | | | 38.1% 18–25 years | 30.0% 18–25 years | 14.8% 18–25 years | 17.1% 18–25 years
| | | | 35.7% 35–45 years | 35.4% 35–45 years | 12.6% 35–45 years | 16.3% 35–45 years
| | | | 30.8% 45–55 years | 38.9% 45–55 years | 16.5% 45–55 years | 13.8% 45–55 years
| | | | 19.3% 55–65 years | 46.8.3% 55–65 years | 21.0% 55–65 years | 13.0% 55–65 years
| | | | 16.7% 65–75 years | 53.8% 65–75 years | 22.6% 65–75 years | 6.9% 65–75 years
| | | | 13.2% 76+ years | 56.3% 76+ years | 22.4% 76+ years | 8.1% 76+ years

Table 5 Pooled prevalence of UI in women by type of incontinence (random effects model, statistical test for heterogeneity between studies significant for all estimates)

Age | Stress | | Urge | | Mixed
| | Prevalence (95% CI) | | Prevalence (95% CI) | | Prevalence (95% CI)
19–44 | 15 studies | 12.8 | 14 studies | 4.9 | 10 studies | 7.1
| Samuelsson, 1997 ^57^ | (8.3; 17.4) | Samuelsson, 1997 ^57^ | (3.7; 6.1) | Samuelsson, 1997 ^57^ | (5.2; 9.1)
| Foldspang, 1999 ^64^ | US* | Foldspang, 1999 ^64^ | US* | Foldspang, 1999 ^64^ | US*
| Hannestad, 2000 ^80^ | 20.1 | Hannestad, 2000 ^80^ | 4.2 (1.3; 7.1) | Hannestad, 2000 ^80^ | 18
| Peyrat, 2002 ^85^ | (5.8; 34.2) | Peyrat, 2002 ^85^ | | Peyrat, 2002 ^85^ | (5.1; 30.9)
| Van der Vaart, 2002 ^91^ | | Van der Vaart, 2002 ^91^ | | Chen, 2003 ^95^
| Chen, 2003 ^95^ | | Chen, 2003 ^95^ | | Rortveit, 2003 ^98^
| Rortveit, 2003 ^98^ | | Rortveit, 2003 ^98^ | | Miller, 2003 ^104^
| Miller, 2003 ^104^ | | Chen, 2003 ^101^ | | Parazzini, 2003 ^108^
| Parazzini, 2003 ^108^ | | Miller, 2003 ^104^ | | Nygaard, 2005 ^130^ *
| Mawajdeh, 2003 ^109^ | | Parazzini, 2003 ^108^ | | Irwin, 2006 ^145^
| Andersson, 2004 ^37^ | | Andersson, 2004 ^37^
| Nygaard, 2005 ^130^ * | | Nygaard, 2005 ^130^ *
| Rohr, 2005 ^133^ | | Rohr, 2005 ^133^
| Irwin, 2006 ^145^ | | Irwin, 2006 ^145^
| Melville, 2005 ^124^ *
45–64 | 36 studies | 21.5 | 32 studies | 10.2 | 20 studies | 12.7
| Burgio, 1991 ^44^ * | (18.9; 24.1) | Burgio, 1991 ^44^ * | (8.9; 11.5) | Burgio, 1991 ^44^ * | (10.9; 14.5)
| Mommsen, 1994 ^51^ | US* | Mommsen, 1994 ^51^ | US* | Mommsen, 1994 ^51^ | US*
| Samuelsson, 1997 ^57^ | 20.2 | Samuelsson, 1997 ^57^ | 8.2 | Samuelsson, 1997 ^57^ | 14.7
| Bogren, 1997 ^61^ | (15.7; 24.8) | Bogren, 1997 ^61^ | (6.3; 10) | Kuh, 1999 ^70^ | (10; 19.3)
| Kuh, 1999 ^70^ | | Kuh, 1999 ^70^ | | Moller, 2000 ^73^
| Moller, 2000 ^73^ | | Moller, 2000 ^73^ | | Ueda, 2000 ^74^
| Ueda, 2000 ^74^ | | Ueda, 2000 ^74^ | | Hannestad, 2000 ^80^
| Temml, 2000 ^75^ | | Temml, 2000 ^75^ | | Peyrat, 2002 ^85^
| Swithinbank, 1999 ^77^ | | Swithinbank, 1999 ^77^ | | Chen, 2003 ^95^
| Alling Moller, 2000 ^78^ | | Alling Moller, 2000 ^78^ | | Miller, 2003 ^104^
| Hannestad, 2000 ^80^ | | Hannestad, 2000 ^80^ | | Parazzini, 2003 ^108^
| Muscatello, 2001 ^84^ | | Muscatello, 2001 ^84^ | | Ozerdogan, 2004 ^116^
| Peyrat, 2002 ^85^ | | Peyrat, 2002 ^85^ | | Melville, 2005 ^124^ *
| van der Vaart, 2002 ^87^ | | van der Vaart ^87^ | | Kocak, 2005 ^127^
| Sze, 2002 ^89^ * | | Sze, 2002 ^89^ * | | Tegerstedt, 2005 ^129^
| Chen, 2003 ^95^ | | Chen, 2003 ^95^ | | Thom, 2006 ^137^ *
| Miller, 2003 ^104^ | | Stewart, 2003 ^102^ * | | Wehrberger, 2006 ^139^ *
| McGrother, 2004 ^38^ | | Miller, 2003 ^104^ | | Irwin, 2006 ^145^
| Andersson, 2004 ^37^ | | Parazzini, 2003 ^108^ | | Waetjen, 2007 ^149^ *
| Ozerdogan, 2004 ^116^ | | Andersson, 2004 ^37^ | | Kinchen, 2007 ^148^ *
| Corcos, 2004 ^117^ | | Ozerdogan, 2004 ^116^
| Vandoninck, 2004 ^122^ | | Corcos, 2004 ^117^
| Melville, 2005 ^124^ * | | Melville, 2005 ^124^ *
| Kocak, 2005 ^127^ | | Ruff, 2005 ^126^ *
| Tegerstedt, 2005 ^129^ | | Kocak, 2005 ^127^
| Teleman, 2005 ^131^ | | Tegerstedt, 2005 ^129^
| Fritel, 2005 ^135^ | | Teleman, 2005 ^131^
| Goldberg, 2005 ^136^ * | | Thom, 2006 ^137^ *
| Thom, 2006 ^137^ * | | Wehrberger, 2006 ^139^ *
| Wehrberger, 2006 ^139^ * | | Irwin, 2006 ^145^
| Lukacz, 2006 ^141^ * | | Waetjen, 2007 ^149^ *
| Irwin, 2006 ^145^ | | Kinchen, 2007 ^148^ *
| Waetjen, 2007 ^149^ *
| Kinchen, 2007 ^148^ *
65+ | 31 studies | 16.1 | 28 studies | 12.2 | 19 studies | 16.8 (13.7; 19.9)
| Nygaard, 1996 ^56^ * | (13.7; 18.6) | Nygaard, 1996 ^56^ * | (9.9; 14.5) | Thom, 1997 ^59^ * | US*
| Thom, 1997 ^59^ * | US* | Thom, 1997 ^59^ * | US* | Damian, 1998 ^35^ | 17.8
| Bogren, 1997 ^61^ | 15.9 | Bogren, 1997 ^61^ | 13.3 | Brown, 1999 ^66^ * | (12.9; 23)
| Koyama, 1998 ^63^ | (12.4; 19.5) | Koyama, 1998 ^63^ | (9.7; 16.8) | Stenberg, 1999 ^71^
| Damian, 1998 ^35^ | | Damian, 1998 ^35^ | | Bortolotti, 2000 ^72^
| Brown, 1999 ^66^ * | | Brown, 1999 ^66^ * | | Ueda, 2000 ^74^
| Stenberg, 1999 ^71^ | | Stenberg, 1999 ^71^ | | Hannestad, 2000 ^80^
| Bortolotti, 2000 ^72^ | | Bortolotti, 2000 ^72^ | | Peyrat, 2002 ^85^
| Ueda, 2000 ^74^ | | Ueda, 2000 ^74^ | | Buchsbaum, 200 ^90^ *
| Hannestad, 2000 ^80^ | | Hannestad, 2000 ^80^ | | Miller, 2003 ^104^
| Muscatello, 2001 ^84^ | | Muscatello, 2001 ^84^ | | Nuotio, 2003 ^106^
| Peyrat, 2002 ^85^ | | Peyrat, 2002 ^85^ | | Parazzini, 2003 ^108^
| Buchsbaum, 2002 ^90^ * | | Buchsbaum, 2002 ^90^ * | | Espino, 2003 ^110^ *
| Dallosso, 2003 ^103^ | | Miller, 2003 ^104^ | | Adelmann, 2004 ^30^ *
| Miller, 2003 ^104^ | | Nuotio, 2003 ^106^ | | Oskay, 2005 ^121^
| Nuotio, 2003 ^106^ | | Parazzini, 2003 ^108^ | | Jackson, 2005 ^128^ *
| Parazzini, 2003 ^108^ | | Espino, 2003 ^110^ * | | Tannenbaum, 2006 ^142^
| Espino, 2003 ^110^ * | | Andersson, 2004 ^37^ | | Swanson, 2005 ^143^
| Andersson, 2004 ^37^ | | Jackson, 2004 ^118^ * | | Irwin, 2006 ^145^
| Jackson, 2004 ^118^ * | | Adelmann, 2004 ^30^ *
| Adelmann, 2004 ^30^ * | | Oskay, 2005 ^121^
| Oskay, 2005 ^121^ | | Jackson, 2004 ^123^ *
| Jackson, 2004 ^123^ * | | Bradley, 2005 ^125^ *
| Bradley, 2005 ^125^ * | | Jackson, 2005 ^128^ *
| Jackson, 2005 ^128^ * | | Rohr, 2005 ^133^
| McGrother, 2006 ^132^ | | Tannenbaum, 2006 ^142^
| Rohr, 2005 ^133^ | | Swanson, 2005 ^143^
| Tannenbaum, 2006 ^142^ | | Irwin, 2006 ^145^
| Swanson, 2005 ^143^
| Irwin, 2006 ^145^
| Melville, 2005 ^124^ *
80+ | 7 studies | 15.9 | 4 studies | 11.4 | 7 studies | 15.9
| Melville, 2005 ^124^ * | (7.9; 23.9) | Stenberg, 1999 ^71^ | (5.5; 17.4) | Stenberg, 1999 ^71^ | (7.3; 24.4)
| Stenberg, 1999 ^71^ | US* | Ueda, 2000 ^74^ | US | Ueda, 2000 ^74^ | US*
| Ueda, 2000 ^74^ | 8.4 | Hannestad, 2000 ^80^ | 10.9 | Hannestad ^80^ | 28.9
| Hannestad, 2000 ^80^ | (8.3; 8.4) | Melville, 2005 ^124^ * | (10.9; 10.9) | Muscatello, 2001 ^84^ | (28.9; 29)
| Muscatello, 2001 ^84^ | | | | Nuotio, 2003 ^106^
| McGrother, 2004 ^38^ | | | | Rohr, 2005 ^133^
| Rohr, 2005 ^133^ | | | | Melville, 2005 ^124^ *

* Studies conducted in the U.S.

A small number of population-based surveys conducted in the United States have compared racial/ethnic differences in UI types. ^89,^ ^118,^ ^137,^ ^149^ In general, White women have higher rates of stress UI than Black, Hispanic, or Asian women, ^89,^ ^149^ although one study did find Hispanic women had a higher rate of stress UI than White, Black, and Asian women. ^137^ Black women are more likely to have higher rates of urge UI and mixed UI as compared to Whites and Hispanics. ^137,^ ^149^

### Incidence of UI in Community Dwelling Women

There are limited data from 18 studies on the incidence of UI in community dwelling women (Table 6). ^38,^ ^45,^ ^47,^ ^56,^ ^59,^ ^62,^ ^103,^ ^134,^ ^139,^ ^149^ – ^157^ Variations in incidence rates can be attributed to differences in study populations, UI definition, followup periods, and reporting methods. One-year incidence rates varied from <1 percent in Norwegian women ages 50–74 years ^62^ to 26 percent in American women ages 20–84 years. ^139^ Annual cumulative incidence rates averaged between 1–4 percent, ^139,^ ^153,^ ^155^ with rates increasing with advancing age. ^33,^ ^38,^ ^139^ In one study that examined incidence rates with respect to age, the incidence increased from 8 percent in women ages 40–49 years to 15 percent in those 80 years and over, ^38^ whereas in another study, rates increased from 15 percent in women ages 20–36 years to 47 percent in women 70 years and over. ^139^ There is a paucity of studies examining racial/ethnic differences in UI incidence rates. In one study, Whites had a slightly higher annual cumulative incidence (13 percent) than Black women (12 percent). ^149^

Table 6 Incidence of UI in community dwelling adults

Author | Country | Ages (years) | Response Rate | Number | Followup | Urinary Incontinence Definition | Incidence (%) | Annual Cumulative Incidence Rate (%)
Women and Men Combined
Liu, 2002 ^33^ | China | 70 years & over | 53.4 | 2,087 | 1 and 2 years | Difficulty holding urine until getting to the toilet (urge UI) and accidentally passing urine (stress UI) | 1-year:
| | | | | | | 19.8% urge UI at least occasionally
| | | | | | | 3.1% urge UI often
| | | | | | | 14.5% stress UI at least occasionally
| | | | | | | 1.9% stress UI often
| | | | | | | 2-years:
| | | | | | | 33.7% urge UI at least occasionally
| | | | | | | 25.4% stress UI at least occasionally
McGrother, 2004 ^38^ | UK | 40 years & over | 60.2% | 39,602 | 1 year | Daytime or nighttime leakage | 6.3%
Mardon, 2006 ^39^ | USA | 65 years & over | 67% to initial survey | 58,658 | 2 years | Urine loss in past 6 months | 37.3%
| | | 82% to followup survey
Women
Herzog, 1990 ^47^ | USA | 60 years & over | 66–72 | 1,956 | 1 and 2 years | Urine loss over past 12 months | 22.4% at 1 year
| | | | | | | 18.6% at 2 years
Burgio, 1991 ^45^ | USA | 42–51 years | 60 | 486 | 3 years | Urine leakage at least monthly | 8%
Nygaard, 1996 ^56^ | USA | 65 years & over | — | 2,025 | 3 years | Difficulty holding urine until getting to toilet or urine leakage with exertion | 28.6% Stress UI
| | | | | | | 28.5% Urge UI
Thom, 1997 ^59^ | USA | 65 years & over | — | 3,004 | 9 years | UI diagnosis in medical record | Rate/1,000 person-years:
| | | | | | | 23.0 overall
| | | | | | | 7.7 65–74 years
| | | | | | | 20.2 75–79 years
| | | | | | | 30.9 80+ years
Holtedahl, 1998 ^62^ | Norway | 50–74 years | 70% | 489 | 1 year | Any urine leakage, regular leakage (≥2 episodes/ month) with or without objective demonstration; and regular incontinence, ICS definition fulfilled | 0.6%
Møller, 2000 ^150^ | Denmark | 40–60 years | 71.5 | 2,284 | 1 year | Stress, urge, and mixed incontinence | 4.0% Stress UI
| | | | | | | 2.7% Urge UI
| | | | | | | 5.8% Mixed UI
Samuelsson, 2000 ^151^ | Sweden | 20–59 years | 77 | 491 | 5 years | Involuntary urine loss | 13.7% | 2..9% (any)
| | | | | | | | 0.5% (weekly)
Sherburn, 2001 ^152^ | Australia | 45–55 years | — | 1,897 | 7 years | Involuntary urine loss | 35%
Liu, 2002 ^33^ | China | 70 years & over | 53.4 | 2,087 women and men combined | 1 and 2 years | Difficulty holding urine until getting to the toilet (urge UI) and accidentally passing urine (stress UI) | Stress UI at 1 year:
| | | | | | | 1.9% often
| | | | | | | 15.9% occasional
| | | | | | | 16.5% at least occasional
| | | | | | | Urge UI at 1 year:
| | | | | | | 2.1% often
| | | | | | | 12.6% occasional
| | | | | | | 14.5% at least occasional
| | | | | | | At 2-years (at least occasionally):
| | | | | | | 30.8% Stress UI
| | | | | | | 37.5% Urge UI
Dallosso, 2003 ^103^ | UK | 40 years & over | 65.3% Baseline | 6,426 | 1 year | Stress urinary leakage several times a month | 8.3%
| | | 91.2% at 1 year
Grodstein, 2004 ^153^ | USA | 50–75 years | Prospective cohort with mailed questionnaire | 39,436 | 4 years | Urine leakage 1–3 times/month; frequent UI over past 12 months: at least once/week | 3% ages 50–55 | 3.2% per year for occasional incontinence
| | | | | | | | 1.6% for frequent incontinence
Hagglund, 2004 ^155^ | Sweden | 22–50 years | 73% | 248 | 4 years | Involuntary urine loss at present time | 17% | 4%
McGrother, 2004 ^38^ | UK | 40 years & over | 79.8% | 9,598 | 1 year | Involuntary urine leakage (day or night) ever | 8.8% overall
| | | | | | | 8.4% 40–49 years
| | | | | | | 7.9% 50–59 years
| | | | | | | 8.5% 60–69 years
| | | | | | | 9.4% 70–70 years
| | | | | | | 14.7% ≥ 80 years
Lifford, 2005 ^134^ | USA | 50–75 years | 88.5% | 47,461 | 4 years | Urine leakage at least weekly | 6.2%
| | | | | | | 7.0% without diabetes
| | | | | | | 10.5% with diabetes
Jackson, 2006 ^144^ | USA | 55–75 years | — | 1,107 | 1 and 2 years | Urine leakage during past year | At 1-year:
| | | | | | | 21% without diabetes
| | | | | | | 26% with diabetes
| | | | | | | At 2-years
| | | | | | | 24% without diabetes
| | | | | | | 20% with diabetes
Wehrberger, 2006 ^139^ | Austria | 20–84 years | 47.7% | 441 | 6.5 years | Urine leakage during past 4 weeks | 25.6% | 3.9% annually
| | | | | | | 14.8% 20–39 years | 2.3% 20–39 years
| | | | | | | 25.7% 40–49 years | 4.0% 40–49 years
| | | | | | | 23.6% 50–59 years | 3.6% 50–59 years
| | | | | | | 23.9% 60–69 years | 3.7% 60–69 years
| | | | | | | 47.3% ≥70 years | 7.3% ≥70 years
Danforth, 2007 ^156^ | USA | 54–79 years | — | 31,355 | 2 years | Urine leakage | 2,355 cases
Waetjen, 2007 ^149^ | USA | 40–55 years | 81.8 | 3,302 Baseline | Annually for 5 years | Urine leakage at least monthly | 55.7% Overall | 11.1% any incontinence
| | | | 2,702 Followup | | | 65.2% White | 1.2% severe incontinence
| | | | | | | 58.2% Blacks | 11.6% Blacks
| | | | | | | 43.8% Japanese | 13.4% Whites
| | | | | | | 34.0% Hispanic
Men
Herzog, 1990 ^47^ | USA | 60 years & over | 69% and 72% | 1,956 | 1and 2 years | Urine loss over past 12 months | 9.0% at 1 year
| | | | | | | 9.2% at 2 years
Thom, 1997 ^59^ | USA | 65 years & over | — | 2,982 | 9 years | UI diagnosis in medical record | Rate/1,000 person-years:
| | | | | | | 23.8 overall
| | | | | | | 7.0 65–74 years
| | | | | | | 17.8 75–79 years
| | | | | | | 37.2 80+ years
Liu, 2002 ^33^ | China | 70 years & over | 53.4 | 2,087 women and men combined | 1 and 2 years | Difficulty holding urine until getting to the toilet (urge UI) and accidentally passing urine (stress UI) | Stress UI at 1 year:
| | | | | | | 2.2% often
| | | | | | | 9.7% occasional
| | | | | | | 11.9% at least occasional
| | | | | | | Urge UI at 1 year:
| | | | | | | 3.9% often
| | | | | | | 13.5% occasional
| | | | | | | 17.4% at least occasional
| | | | | | | At 2-years (at least occasionally):
| | | | | | | 20.7% Stress UI
| | | | | | | 30.4% Urge UI
McGrother, 2004 ^38^ | UK | 40 years & over | 77.6% | 7,823 | 1 year | UI as involuntary leakage of urine | 3.8% overall
| | | | | | | 2.2% 40–49 years
| | | | | | | 2.5% 50–59 years
| | | | | | | 4.0% 60–69 years
| | | | | | | 7.1% 70–79 years
| | | | | | | 10.9% ≥80 years

Pooled annual incidence (Table 7) was 6.25 percent (95 percent CI 5.57; 6.93) for all ages with the highest in elderly women, 7 percent (95 percent CI 6.12; 9.37) in those older than 65 years, and 8.52 percent in women over 80 (95 percent CI 3.07; 13.98). Few surveys on the incidence of UI in women have included questions on incontinence types (Figure 2). One study involving 2,283 women ages 40–60 reported a 1-year incident rate for stress UI of 4 percent. ^73^ In a survey of 2,025 women ≥65 years, the 3-year incidence rate for stress and urge UI was 29 percent each. ^56^ In a recent survey in the United States involving 3,302 women ages 40–55 years, the 5-year cumulative incidence rates were highest for stress UI (25 percent), followed by urge UI (16 percent) and mixed UI (12 percent); other or unclassified UI had the lowest incidence rate (3 percent). ^149^ In this same survey, Whites and Japanese-American women had the highest incidence of stress UI compared to Chinese, Hispanic, and Black women. White women also had the highest incidence of urge UI; however, Black women had a higher incidence than Chinese, Japanese, and Hispanic women, respectively. Black women had the highest incidence of mixed UI, followed by White, Chinese, Hispanic, and Japanese women.

Table 7 Pooled annual incidence of UI in women (random effects model) 18 studies

Age categories | Annual incidence (95% CI)
19–44 | 1.64 (0.76; 2.52)
45–64 | 5.80 (5.02; 6.57)
65+ | 7.74 (6.12; 9.37)
80+ | 8.52 (3.07; 13.98)
All ages | 6.25 (5.57; 6.93)
Burgio, 1991 ^45^
Herzog, 1990 ^47^
Nygaard, 1996 ^56^
Thom, 1997 ^59^
Holtedahl, 1998 ^62^
Moller, 2000 ^150^
Samuelsson, 2000 ^151^
Sherburn, 2001 ^152^
Dallosso, 2003 ^103^
Grodstein, 2004 ^153^
McGrother, 2004 ^38^
Dallosso, 2004 ^154^
Hagglund, 2004 ^155^
Lifford, 2005 ^134^
Wehrberger, 2006 ^139^
Waetjen, 2007 ^149^
Danforth, 2007 ^156^
Townsend, 2007 ^157^

Figure 2. Annual incidence of UI in women by type of incontinence (random effects model)

Overall, middle aged and elderly women developed stress UI more often (pooled annual incidence from 4 studies 9.7 percent, 95 percent CI 5.4; 13.9). Annual incidence of mixed UI was close to stress UI (pooled annual incidence from two studies 7.6 percent, 95 percent CI 4.1; 11.0). Less than 7 percent of women 45–79 years old developed urge UI (pooled annual incidence from three studies 6.44 percent, 95 percent CI 2.3; 10.6).

#### Summary

Evidence from large observational studies from different countries (level of evidence IIB) suggested that UI is a prevalent condition among women of all ages with overall prevalence close to the estimations of the National Health and Nutrition Examination Survey (38 percent). ^9^ Prevalence increased in women older than 45 years of age with further small increases in elderly women. Stress UI is the most prevalent type if UI in women 45–64 years old, while elderly women experienced mixed UI more frequently. Incidence of UI (level of evidence IIA-B) gradually increases with age. Differences in definitions of UI contributed substantially to variability in the results from individual studies.

### Progression and Remission of UI in Community Dwelling Women

There is limited data on the natural history of UI in women. Of the several studies of UI during and following childbirth, most report prevalence rates making it difficult to determine the progression and remission rates of UI in this subpopulation of women. Available data suggest that UI is a dynamic process in women, although the rates for full remission tend to be low. In nonchildbearing populations, annual remission rates range from 3 to 11 percent. ^33,^ ^47,^ ^139,^ ^150,^ ^151,^ ^155^ Remission rates tend to decrease with advancing age, ^150,^ ^155^ with one study reporting women ages 22–30 had remission rates more than twice that of women ages 41–50, 33 and 13 percent, respectively. ^155^ Duration of incontinence did not affect the chance of remission in a study involving women ages 20–59 years; 20 percent in the remission group and 24 percent in the incontinent group had been incontinent for at least 10 years. ^151^ Evidence indicates that the severity of UI tends to worsen over time. ^33,^ ^47^

Data on the progression and remission of the different types of UI is scarce, with variable followup periods making it challenging to summarize remission rates. Data in women ages 60 years and over suggest that when women become incontinent they tend to first develop stress UI, either alone or in combination with urge UI. Those with stress UI alone either continue with stress UI alone or develop mixed UI over a 2-year followup period. ^47^ Some evidence indicates that the type of UI is relatively stable over 3 to 6.5 years, ^56,^ ^139,^ ^155^ particularly for stress UI. One study involving women ages 20–84 years found that the majority of women (52 percent) had the same form of UI after 6.5 years. ^139^ In this study, urge UI had the highest remission rate (38 percent) followed by stress and mixed UI (21 and 15 percent, respectively). In another study of women ages 40–60 years, the 1-year remission rates were 41 percent for stress UI, 42 percent for urge UI, and 38 percent for mixed UI. ^150^ In a study of women ages 65 years and over, the 3-year remission rates were 25 percent for stress UI and 22 percent for urge UI. ^56^ A study examining 10-year incidence and progression rates reported that women ages 70 and over with or without urgency had incontinence rates for urge UI of 11 percent and 15 percent respectively. ^582^ There was also a higher percent of women with urge UI at followup (6 percent at baseline and 26 percent at 10-years).

### Prevalence of UI in Community Dwelling Men

In comparison to women, there have been fewer epidemiological studies in men (Appendix Table F2) with highly variable samples, including age categories and definitions of UI. Although there is a broad age range in the prevalence studies, the majority concentrate on middle age and older male populations (e.g., beginning at age 40, 60, or 65 years and over) ^8,^ ^30,^ ^35,^ ^37,^ ^39,^ ^47,^ ^61,^ ^72,^ ^74,^ ^81,^ ^88,^ ^97,^ ^107,^ ^111,^ ^113^ – ^115,^ ^181,^ ^583^ – ^586^ with fewer studies of men younger than 40 years, ^37,^ ^52,^ ^54,^ ^86,^ ^145,^ ^181,^ ^587^ – ^589^ including a recent national survey of men ages 18 years and over in the United States. ^589^ The majority of these studies have been conducted in North America or European countries using predominantly White populations. Two studies have incorporated Asian populations. ^107,^ ^585^ Pooled analysis (Table 8) detected a clear pattern of increased prevalence of total UI in aging men from 4.8 percent (95 percent CI 3.7; 5.9) in 19–44 years old (11 studies) to 11.2 percent (95 percent CI 10.1; 12.3) in those 45–64 years old (27 studies), to 21.1 percent (95 percent CI 19.9; 22.4) in males over 65 years of age (41 studies). The highest prevalence of UI was reported in elderly males of 32.2 percent (95 percent CI 29.6; 32.7) (17 studies). Urge UI was the most prevalent type of UI in males among all age categories increasing from 3.1 percent (95 percent CI 2.0; 4.2) in 19–44 years old (7 studies) to 11.7 percent (95 percent CI 9.3; 14.1) in those older than 65 years of age (20 studies).

Table 8 Pooled prevalence of total, mixed, stress, and urge male UI among age categories (random effects model)

Age (studies) | Prevalence (95% CI)
19–44 years
Total UI (11) | 4.81 (3.69; 5.94)
Mixed UI (3) | 0.70 (0.11; 1.29)
Stress UI (5) | 0.74 (0.14; 1.34)
Urge UI (7) | 3.09 (1.96; 4.21)
45–64 years
Total UI (27) | 11.20 (10.14; 12.26)
Mixed UI (4) | 1.53 (0.94; 2.12)
Stress UI (13) | 3.78 (1.56; 6.00)
Urge UI (14) | 7.75 (4.99; 10.50)
65+ years
Total UI (41) | 21.13 (19.90; 22.35)
Mixed UI (10) | 6.13 (2.53; 9.74)
Stress UI (15) | 2.67 (1.95; 3.39)
Urge UI (20) | 11.70 (9.27; 14.14)
80+ years
Total UI (17) | 32.17 (29.62; 34.73)
Mixed UI (1) | 9.40 (9.34; 9.46)
Urge UI (3) | 18.18 (6.84; 29.51)

#### Type of UI

The prevalence of UI, defined in various ways (ever, current, any, greater than two times/week, or leakage within past 4 weeks, 2, 6, or 12 months), is estimated between 3 percent in men 30 years and over in a study conducted in the United Kingdom ^52^ to 37 percent in men 39–91 years in a Norwegian study. ^586^ In a large population-based study conducted in five countries (Canada, Germany, Italy, Sweden, and the United Kingdom), the prevalence rate for men ages 18 and over was 5 percent. ^145^

Studies in American men reported UI as involuntary leakage of urine during the last year, last month, or ever (Appendix Table F3). The prevalence estimations varied substantially depending on the definitions, with the higher prevalence of UI during the last year in males 19–44 years old (18.4 percent, 95 percent CI 4.5; 32.2) and 45–64 years old (24.6 percent 95 percent CI 19.92; 29.35) compared to UI during the last month (Table 9). Older males reported UI during the last month more frequently, from 29.2 percent (95 percent CI 24.4; 34.0) among those older than 65 years of age to 42.4 percent (95 percent CI 32.8; 52.0) in elderly males. Two percent of American men 45–64 years old ever experienced stress UI (95 percent CI 2.0; 2.0) and one percent reported stress UI during the last month. Urge UI was the more prevalent during the last year (6.7 percent, 95 percent CI 6.7; 6.7) of men 45–64 years old. Men over 65 years of age reported having urge UI during the last month (10.6 percent, 95 percent CI 10.6; 10.6).

Table 9 Pooled prevalence of UI in American males by definition and age categories (random effects model)

Time when Involuntary leakage of urine was reported (months) (studies) | Prevalence (95% CI)
Total UI | 19–44 years
During last month (1) | 7.21 (7.13; 7.29)
During last year (2) | 18.35 (4.53; 32.17)
| 45–64 years
During last month (2) | 15.52 (11.57; 19.47)
During last year (3) | 24.64 (19.92; 29.35)
Ever (2) | 6.40 (2.62; 15.42)
| 65+ years
During last month (2) | 29.21 (24.44; 33.97)
During last year (5) | 24.38 (19.44; 29.31)
Ever (3) | 16.84 (13.05; 20.63)
| 80+ years
During last month (2) | 42.39 (32.80; 51.99)
During last year (3) | 27.70 (15.49; 39.91)
Ever(3) | 33.98 (27.34; 40.61)
Stress UI | 45–64 years
During last month (1) | 1.00 (1.11; 2.29)
During last year (1) | 1.40 (1.39; 1.41)
Ever (1) | 2.00 (1.99; 2.01)
Urge | 45–64 years
During last month (1) | 2.00 (3.41; 3.43)
During last year (1) | 6.70 (6.68; 6.72)
Ever (1) | 2.60 (2.59; 2.61)
| 65+ years
During last month (1) | 10.60 (10.58; 10.62)
During last year (2) | 8.46 (8.45; 8.48)
Ever (1) | 9.62 (9.58; 9.65)
| 80+ years
During last year (1) | 3.50 (3.46; 3.54)

#### Severity of UI

Fewer studies provided estimates for severity of UI in American men (Appendix Table F4). ^54,^ ^164,^ ^181,^ ^590,^ ^591^ A survey of 922 males older than 20 years who were recruited in the primary care clinic ^54^ reported that wet underwear less than once per month was experienced by 9 percent, monthly by 5 percent, weekly by 7 percent, and daily by 14 percent of the responders. A community-based cross-sectional survey of 778 men older than 40 years ^590^ reported that 10.8 percent of the responders had wet underclothing during the last year. Among males 41–60 years old from primary care clinics in a Veterans Affairs facility, 4.4 to 4.8 percent experienced daily UI. ^181^ The prevalence of daily UI increased to 8.4 to 8.9 percent among those older than 60 years of age. Pooled analysis (Table 10) estimated that daily UI was experienced by 4.8 percent of males 45–64 years (95 percent CI 4.8; 4.8), 8.3 percent men over 65 years old (95 percent CI 7.0; 9.6), and 9.3 percent elderly men (95 percent CI 4.5; 14.1). Severe UI that required a change of underwear was reported by 2 percent of those 45–64 years old and 4 percent of elderly men (95 percent CI 3.9; 4.1).

Table 10 Pooled prevalence of UI in American males by severity and age categories (random effects model)

Frequency and Severity of Leakage Episodes (Studies) | Prevalence (95% CI)
Daily
19–44 years (2) | 3.02 (2.39; 3.66)
45–64 years (1) | 4.80 (4.77; 4.83)
65+ years (2) | 8.30 (7.04; 9.56)
80 and over (2) | 9.33 (4.53; 14.14)
Minimal
19–44 years (1) | 9.00 (8.93; 9.07)
45–64 years (2) | 14.44 (5.74; 23.14)
80 and over (1) | 4.00 (3.93; 4.07)
Moderate
19–44 years (1) | 10.80 (10.79; 10.81)
45–64 years (1) | 8.90 (7.13; 10.67)
65+ years (1) | 5.95 (5.26; 6.64)
80 and over (1) | 12.00 (11.88; 12.12)
Severe
19–44 years (1) | 3.00 (2.96; 3.04)
45–64 years (2) | 2.00 (1.13; 2.87)
65+ years (1) | 1.55 (1.13; 1.98)
80 and over (1) | 4.00 (3.93; 4.07)

#### Racial/ethnic differences

The majority of studies have been conducted in White male populations (Table 1). Three studies from the United States provided data on prevalence rates in racial/ethnic groups using different survey methodology, including methods for estimating prevalence. ^8,^ ^39,^ ^181^ In one large population-based survey using a weighted prevalence estimate, non-Hispanic Black men were found to have a higher rate of UI (21 percent) compared to non-Hispanic White men (16 percent) and Mexican-American men (14 percent). ^8^ In the other study, non-Hispanics (38 percent) were more likely than Hispanics (31 percent) to have UI. ^39^ This latter study also found that American Indians and Whites had higher rates of UI than Asians and Blacks, respectively. A sample of male veterans receiving care in primary care clinics found similar rates of incontinence between Whites (32 percent) and Blacks (33 percent). ^181^ In a cross-national comparison of UI prevalence rates, South Korean men had the lowest rates (4 percent) followed by men in France (7 percent), the United Kingdom (14 percent), and the Netherlands (16 percent). ^585^

### Incidence of UI in Community Dwelling Men

There is scarce data on the incidence of UI in community dwelling men, excluding studies of men following prostatectomy (Table 6). One-year incidence rates vary depending on the age of the study population. In one study of men 40 years and over residing in the United Kingdom, the 1-year incident rate was 4 percent, with incidence of involuntary leakage increasing from 2 percent in those 40–49 years to 11 percent in those 80 years and over. ^38^ In a study of American men 60 years and over, the 1-year incidence rate of involuntary leakage was 20 percent (weighted for nonresponders). ^47^ There are no data available on the incidence of the different types of UI or comparisons by racial/ethnic groups.

#### Progression and remission of UI in community dwelling men

There is limited evidence on the progression and remission of UI in men. Evidence indicates that when men became incontinent, they developed urge or other types of UI; those with urge UI alone either stayed as urge UI or developed mixed UI. ^47^ In one study over a 10-year period, 3 percent of men without either urgency or urgency with incontinence at baseline developed urge UI. There was a slight nonsignificant decline in men with urge UI at baseline to have it at the 10-year followup (5 percent vs. 4 percent, respectively). ^582^

### Epidemiology of UI in Long-Term Care Settings

#### Overview

In contrast to community settings, there have been fewer epidemiological studies on the prevalence, incidence, progression, and remission of UI in LTC settings. Differences in study populations, survey methodology, and definitions and measurement of UI affect the variability in prevalence estimates. Also, the timing of the survey, e.g., at admission or at a later date, also adds to the variability in estimates. More recent studies have relied on the bladder continence item on the Minimum Data Set (MDS) to operationalize UI. Two studies report data from the same cohort but derive slightly different estimates. ^28,^ ^166^ There are scarce data on the severity and impact of UI.

#### Prevalence of UI in the LTC population

The majority of studies sample both men and women ages 65 years and over residing in LTC facilities (Table 11). Although most studies provide prevalence estimates by gender, some provided only a prevalence estimate that included both men and women. For the combined group, prevalence estimates using varying definitions (e.g., any daytime urinary incontinence, at least two episodes of urine loss in the past 2 weeks, urine loss at least twice a month, or medical record or staff report of UI) ranges from 30–77 percent. ^2,^ ^28^ – ^31^ Measuring UI with the MDS, prevalence estimates varied from 30 percent in a large sample of 29,645 adults ages 20–109 years ^31^ to 77 percent in a smaller sample of 380 adults 65 years and over. ^30^ In a recent population-based study involving 95,911 older nursing home residents from eight southeastern states, the prevalence rate at admission was 65 percent. ^32^

Table 11 Prevalence of UI and incontinence types in LTC populations by age, gender, and race

Author | Country | Gender | Ages (years) | Design | Urinary Incontinence Definition | Response Rate (%) | Number | UI Prevalence (%)
Palmer, 1991 ^28^ | USA | Men and women | ≥65 years | Prospective cohort with 1-year follow-up | Any daytime urinary incontinence reported by nursing assistants; those with indwelling catheters were considered incontinent | 45 | 196 | 44.2 (overall at 1 year)
| | | | | | | | 2 weeks after admission:
| | | | | | | | 23 men
| | | | | | | | 77 women
Borrie, 1992 ^34^ | Canada | Men and women | | | Urinary incontinent episodes occurring 1–2 times a week or more | — | 457 | 62
Ouslander, 1993 ^166^ | USA | Men and women | ≥65 years | Prospective cohort of new admissions in 8 nursing homes | Any daytime urinary incontinence reported by nursing assistants; those with indwelling catheters were considered incontinent | 81 of eligible residents | 454 | 39 (overall)
| | | | | | | | Incidence:
| | | | | | | | 27% at 2 months
| | | | | | | | 19% at 1 year
Brandeis, 1997 ^164^ | USA | Men and women | ≥60 years | Random sample from 270 nursing homes in 10 states; used MDS data | At least 2 episodes of involuntary urine loss within past 2 weeks | 92.6 | 2,014 | 49 (overall)
| | | | | | | | 45.1 men
| | | | | | | | 78.4 women
Adelmann, 2004 ^30^ | USA | Men and women | ≥65 years | Random sample of Medicaid enrollees in one metropolitan area; used MDS data | Any non-zero response on MDS question related to bladder incontinences | | 380 | 77.2 (overall)
| | | | | | | | 78.4 women
| | | | | | | | 72.0 men
| | | | | | | | 61.2% 65–74 years
| | | | | | | | 75.0% 75–84 years
| | | | | | | | 82.7% 85+ years
| | | | | | | | 77.1 White
| | | | | | | | 72.7 Black
| | | | | | | | 87.5 Other
Aggazzotti, 2000 ^29^ | Italy | Men and women | Not reported | Cross-sectional survey using clinical records and questionnaires | Involuntary urine loss at least twice a month | 89.8 | 839 | 54.5 (overall)
| | | | | | | | 59.8 women (overall)
| | | | | | | | 42.9 <65 years
| | | | | | | | 55.1 65–74 years
| | | | | | | | 58.1 75–84 years
| | | | | | | | 60.1 85–94 years
| | | | | | | | 76.0 ≥95 years
| | | | | | | | 39.2 men (overall)
| | | | | | | | 19.1 <65 years
| | | | | | | | 22.7 65–74 years
| | | | | | | | 51.8 75–84 years
| | | | | | | | 52.4 85–94 years
| | | | | | | | 57.1 ≥95 years
Jumadilova, 2005 ^31^ | USA | Men and women | 20–109 years; mean age 78 | Cross-sectional database analysis using MDS data from 378 nursing homes | The MDS question on bladder incontinence (Section H, 1.b) was used to classify patients on level of UI, with 0 (no incontinence) to 4 (incontinent most of the time). | — | 29,645 | 30% (overall-UI alone)
| | | | | | | | 58% (UI and FI)
Anger, 2006 ^2^ | USA | Women | Not reported | National population-based survey using the National Nursing Home Survey | Admission or current diagnosis of urinary incontinence in medical records; also staff survey on residents who had difficulty in controlling urination | Not reported | 1,125, 163 in 1995 | 1,366 per 100,000 (<1.4%) as identified in medical record
| | | | | | | 1,156, 1,134 in 1997 | 73.8% to 85.4% as identified by the National Nursing Home Survey
| | | | | | | 1,170,065 in 1999 | 56.3% to 58.6% had difficulty controlling urination
| | | | | | | | 9.5% to 11.7% had indwelling urethral catheter or ostomy
| | | | | | | | Averaged over 3 waves by age:
| | | | | | | | 15.6% ≤ 4 years
| | | | | | | | 36.2% 75–84 years
| | | | | | | | 48.3% ≥ 5 years
| | | | | | | | Of incontinent women:
| | | | | | | | 83.7% were White, 11% Black, and 2.8% were Hispanic
Boyington, 2007 ^32^ | USA | Men and women | ≥65 years | Population-based sampling involving nursing homes from 8 states | Any non-zero response on the MDS bladder incontinence item indicating incontinent episodes occurring once a week or more | NA | 95,911 | 65.4% at admission
| | | | | | | | 64.1% Whites
| | | | | | | | 71.2% Blacks
| | | | | | | | 74.3% post-admission
| | | | | | | | 73.5% Whites
| | | | | | | | 78.2% Blacks
| | | | | | | | 75.0% women
| | | | | | | | 72.2% men
| | | | | | | | Progression - 8.9%
Liu ^33^ | Australia | Men and women | ≥70 years | The State Electoral Data Base survey at three years | SUI, UUI, or MUI | 53.4 | 4187 | Males
| | | | | | | | 1 time point | Urge | Stress
| | | | | | | | Often | 6.6 | 2.3
| | | | | | | | Occasionally | 25.2 | 15.8
| | | | | | | | 2 time point | Urge | Stress
| | | | | | | | Often | 8.5 | 4.7
| | | | | | | | Occasionally | 22.1 | 13.7
| | | | | | | | 3 time point | Urge | Stress
| | | | | | | | Often | 6.2 | 4.2
| | | | | | | | Occasionally | 29 | 17.7
| | | | | | | | Females
| | | | | | | | 1 time point | Urge | Stress
| | | | | | | | Often | 10.2 | 4.4
| | | | | | | | Occasionally | 31.2 | 24.6
| | | | | | | | 2 time point | Urge | Stress
| | | | | | | | Often | 10.6 | 5.3
| | | | | | | | Occasionally | 32 | 23.6
| | | | | | | | 3 time point | Urge | Stress
| | | | | | | | Often | 8.9 | 5.3
| | | | | | | | Occasionally | 39.1 | 30.1
| | | | | | | | Total
| | | | | | | | 1 time point | Urge | Stress
| | | | | | | | Often | 8.4 | 3.3
| | | | | | | | Occasionally | 28.2 | 20.1
| | | | | | | | 2 time point | Urge | Stress
| | | | | | | | Often | 9.6 | 5.0
| | | | | | | | Occasionally | 27 | 18.6
| | | | | | | | 3 time point | Urge | Stress
| | | | | | | | Often | 7.5 | 4.8
| | | | | | | | Occasionally | 34.1 | 24
| | | | | | | | Total age adjusted
| | | | | | | | 1 time point | Urge | Stress
| | | | | | | | Often | 7.7 | 2.9
| | | | | | | | Occasionally | 27.5 | 19.5
| | | | | | | | 2 time point | Urge | Stress
| | | | | | | | Often | 9.4 | 4.2
| | | | | | | | Occasionally | 25.7 | 17.5
| | | | | | | | 3 time point | Urge | Stress
| | | | | | | | Often | 6.7 | 4.1
| | | | | | | | Occasionally | 33 | 22.9
| | | | | | | | Time: | 1 | 2 | 3 | all
| | | | | | | | Urge | 17.6 | 15 | 19.9 | 17.4
| | | | | | | | Stress | 4.5 | 2.0 | 6.9 | 4.4
| | | | | | | | Mixed | 18.9 | 21.6 | 21.8 | 20.6
| | | | | | | | Incidence in males at 12 months:
| | | | | | | | | Urge | Stress
| | | | | | | | Often | 3.9 | 2.2
| | | | | | | | Occasional | 13.5 | 9.7
| | | | | | | | Incidence in females at 12 months:
| | | | | | | | | Urge | Stress
| | | | | | | | Often | 2.1 | 1.6
| | | | | | | | Occasional | 20.5 | 15.9
| | | | | | | | Incidence of Urge
| | | | | | | | Males | 20.9
| | | | | | | | Females | 21.8
| | | | | | | | Total | 21.2
| | | | | | | | Incidence of Stress
| | | | | | | | Males | 17.3
| | | | | | | | Females | 21.9
| | | | | | | | Total | 19.6
| | | | | | | | Progression of urge
| | | | | | | | Males | 2
| | | | | | | | Females | 3
| | | | | | | | Total | 2.5
| | | | | | | | Progression of stress
| | | | | | | | Males | 1.1
| | | | | | | | Females | 1.9
| | | | | | | | Total | 1.5
Borrie, 1992 ^34^ | UK | Men and women | Mean age: men 73.6 years; women 73.8 years | Prevalence survey in long-term care hospital | 1) Fully continent (completely independent);; 2) Dry but staff assistance required;; 3) One to two incontinent events/week;; 4) 3 to 7 incontinent events per week;; 5) 2 to 4 incontinent events/24 hours;; 6) Always incontinent (includes the need for an indwelling urinary catheter and an external urinary drainage device). | 95% | 457 | 62% Men and women
| | | | | | | | 61% Men
| | | | | | | | 65 % Women
Nelson, 2005 ^4^ | USA | Men and women | Mean age 85.9 years | Wisconsin annual nursing home survey | Resident-based MDS definition; continence of urine - complete control of the bladder and no indwelling urinary catheter. UI - usually, occasionally, frequently or always incontinent, or had an indwelling urinary catheter. | Lost to followup from 1992 to 1993 43.2% | 18,170 nursing | 55.4% 1992
| | | | | | | | 61.5% 1993
| | | | | | | | Incidence 23.6%/year
Peet, 1995 ^519^ | UK | Men and women | >65 years; Mean age 82.7 years | Survey of long term care in Leicestershire | Urine incontinence | 95% | 627 | | Type of LTC
| | | | | | | 446 | 20.7 | acute
| | | | | | | 397 | 30.9 | geriatric
| | | | | | | 1,704 | 28.2 | psychogeriatric
| | | | | | | 1,244 | 21.3 | local authority
| | | | | | | 946 | 19.1 | private residential
| | | | | | | 192 | 29.7 | private nursing
| | | | | | | 202 | 6.3 | voluntary sector
| | | | | | | 5,758 | 15.3 | LTC hospitals
| | | | | | | | 22.7 | total
Chiang, 2000 ^600^ | USA | Men and women | Mean age 84 years | Survey of 20 nursing homes in 3 West Coast states using chart abstraction or review of Minimum Data Set | Incontinence status using MDS 6-point scale, dichotomized as being present to any degree versus absent of complete urinary control. | | 464 | 13%
Buchanan, 2002 ^601^ | USA | Men and women | Mean age 76.4 years | Retrospective analysis of MDS admission assessments from June 23, 1998 through September 11, 2000, for nursing home residents receiving hospice care | Incontinence status using MDS scale | | 40,622 | Continent 54.4%
| | | | | | | | Usually continent 5.9%
| | | | | | | | Occasionally incontinent 6.3%
| | | | | | | | Frequently incontinent 9.4%
| | | | | | | | Incontinent 24.0%
Bliss, 2006 ^5^ | USA | Men and women | Mean age 83 years | Cross-sectional analysis of MDS data base in 1999 | Incontinence status using MDS 3-point scale | | 59,558 | 7.7

The prevalence of UI in female residents in LTC settings is estimated at between 60 and 78 percent. ^28^ – ^30,^ ^32,^ ^164^ In one study using data from the National Nursing Home Survey, the prevalence in women was estimated to be 74–85 percent. ^2^ However, in this same study when UI was identified from the medical record, the prevalence rate was <1 percent (1,366 per 100,000). The prevalence of UI in men ranges from 23–72 percent. ^28^ – ^30,^ ^32,^ ^164^

Prevalence rates increase with advancing age in both men and women. ^2,^ ^29,^ ^30^ There is limited data available on racial/ethnic differences in UI prevalence. Those studies available indicate conflicting findings. In one large study involving nursing home residents from eight states, there was a higher prevalence in Blacks (71 percent) compared to Whites (64 percent) at admission, but after admission the prevalence rate was more similar (78 percent vs. 74 percent, respectively. ^32^

#### Incidence of UI in LTC settings

Minimal data are available on the incidence of UI in LTC settings An early study involving 430 nursing home residents reported an incidence of 27 percent 2 months after admission and 19 percent at 1 year. ^166^ This is consistent with a later study that reported an incidence rate of 20 percent at 1 year. ^33^ The incidence of daytime UI between 2 months and 1 year after admission was higher in males (46 percent) than in females (16 percent). ^166^

#### Progression and remission of UI in LTC settings

Few studies have examined the progression and remission of UI in LTC settings in a way that can be easily interpreted. Although there are no large changes documented, the evidence available suggests that UI is a dynamic condition that does change over time, including improvement. One large study involving nursing home residents from eight states that examined UI at admission and within a 4-year post-admission period reported a 0 percent progression rate. ^32^ In another study, the remission rate at 1 year was reported to be 10 percent. ^33^

## Question 1. What are the Prevalence and Incidence of FI in the Community and LTC Settings?

The absence of a standard and accepted definition of FI has hampered drawing conclusions about the epidemiology of both fecal and dual incontinence. Definitions vary by the inclusion of flatus, severity characteristics of FI, and subjective significance (e.g., requiring FI to be a social or hygienic problem). There is often a lack of data to determine whether dual incontinence is actually present. The ICS recommended analyzing the prevalence of AI, including involuntary loss of flatus, in all age groups because this extended definition gives a more precise estimation of impact of incontinence on quality of life in young adults. ^21^ In this review, prevalence and incidence are reported for any FI (i.e., with or without UI), any AI (i.e., FI and flatus incontinence), dual incontinence, and FI only (without UI) when data are available The authors also reported the prevalence of different types of incontinence (including loss of solid or liquid feces) and severity of incontinence.

### Prevalence of Combined UI and FI in Adults in LTC Settings

Prevalence of combined UI and FI in adults in LTC settings varied from 4 percent ^519^ to 44 percent ^34^ across the studies (Table 12). One of the largest cross-sectional studies of 10,215 older nursing home residents in the United States, identified from the MDS, reported 40 percent prevalence of combined incontinence. ^5^ By contrast, another study found a prevalence of 18 percent, analyzing data from the regional census of older residents. ^519^ Almost half the residents in Canadian LTC hospitals had combined incontinence. ^34^ The prevalence was lower in nursing homes in the United Kingdom (4 percent), and in short-term nursing homes (9 percent). ^519^ Residents in geriatric (27 percent), private nursing (33 percent), and psycho-geriatric nursing homes had higher rates of combined incontinence. ^519^

Table 12 Prevalence of FI in LTC settings

Author | Population Subgroup | Sample Size | Prevalence (%)
Combined UI and FI
Peet, 1995 ^519^ | LTC hospitals | 202 | 7.9
| Nursing homes, local authority | 1,704 | 13.9
| Nursing homes, total | 5,758 | 17.7
| Nursing homes, acute | 627 | 9.4
| Nursing homes, geriatric | 446 | 26.5
| Nursing homes, private nursing | 946 | 32.6
| Nursing homes, private residential | 1,244 | 10.2
| Nursing homes, psychogeriatric | 397 | 36.5
| Nursing homes, voluntary sector | 192 | 4.2
Borrie, 1992 ^34^ | LTC hospital | 457 | 44.0
Nelson, 2005 ^4^ | Nursing homes, incidence | 3,859 | 12.4
Bliss, 2006 ^5^ | Nursing homes | 10,215 | 39.7
FI
Peet, 1995 ^519^ | LTC hospitals | 202 | 4.5
| Nursing homes, local authority | 1,704 | 2.9
| Nursing homes, total | 5,758 | 3.1
| Nursing homes, acute | 627 | 4.2
| Nursing homes, geriatric | 446 | 2.7
| Nursing homes, private nursing | 946 | 4.3
| Nursing homes, private residential | 1,244 | 2.9
| Nursing homes, psychogeriatric | 397 | 1.8
| Nursing homes, voluntary sector | 192 | 0.5
Borrie, 1992 ^34^ | LTC hospital | 457 | 46.0
| LTC hospital, Assistance required | 59 | 42.0
| LTC hospital, Cerebrovascualr diseases | 113 | 42.0
| LTC hospital, COPD | 52 | 31.0
| LTC hospital, Dementia | 139 | 66.0
| LTC hospital, Diabetes | 51 | 45.0
| LTC hospital, Hypertension | 40 | 45.0
| LTC hospital, Immobile | 233 | 67.0
| LTC hospital, Independent | 110 | 13.0
| LTC hospital, residents with Ischemic heart disease | 58 | 41.0
| LTC hospital, residents with malignant neoplasm | 34 | 32.0
| LTC hospital, residents with mild mental impairment | 96 | 31.0
| LTC hospital, residents with moderate mental impairment | 78 | 68.0
| LTC hospital, residents with multiple sclerosis | 25 | 48.0
| LTC hospital, residents with no mental impairment | 140 | 14.0
| LTC hospital, residents with Parkinson's disease | 40 | 62.0
| LTC hospital, residents with prostate disease | 28 | 50.0
| LTC hospital, residents with severe mental impairment | 123 | 83.0
| LTC hospital, supervised residents | 33 | 27.0
Brocklehurst, 1998 ^602^ | Nursing homes | 497 | 52.0
Nelson, 1998 ^3^ | Nursing home | 18,170 | 46.0
Nelson, 2005 ^4^ | Nursing homes, incidence | 3,850 | 14.7
Bliss, 2006 ^5^ | Nursing homes | 10,215 | 12.4
Wear Pad
Peet, 1995 ^519^ | Long term care hospitals | 202 | 45.2
| Nursing homes | 1,704 | 45.5
| Nursing homes | 5,758 | 49.3
| Nursing homes, acute | 627 | 17.4
| Nursing homes, geriatric | 446 | 48.7
| Nursing homes, private nursing | 946 | 52.5
| Nursing homes, private residential | 1,244 | 55.6
| Nursing homes, psychogeriatric | 397 | 67.7
| Nursing homes, voluntary sector | 192 | 51.5

### Prevalence of FI with or without UI in Adults in LTC Settings

Prevalence of FI with or without UI in adults in LTC settings varied from less than 5 percent across nursing homes in the United Kingdom ^519^ to 12 percent in the largest national American study. ^5^ One study at the state level reported a prevalence of 46 percent ^3^ and an annual incidence of FI in nursing homes of 14 percent. ^4^ The prevalence varied depending on baseline disease, from 27 percent in residents who needed supervision to 83 percent in patients with severe mental impairment. ^34^ More than half of the residents in geriatric and psycho-geriatric LTC facilities wear pads for FI. ^519^ The prevalence depended on the definitions of incontinence and whether having only FI (versus combined UI and FI) was reported (Appendix Table F5). Moderate FI was reported in 8 percent of women in nursing homes. ^161^ Thirteen percent of residents experienced incontinent episodes 1–3 days per week, 16 percent 4–7 days per week, and 23 percent less than once a week. ^602^ Frail residents (16 percent) and patients with stroke (25 percent) and dementia (45 percent) had the highest prevalence of frequent FI. ^602^

In conclusion, fecal and combined incontinence is prevalent in LTC facilities. Combined incontinence is more prevalent than FI alone. Rates depend on the data set, definitions and severity of incontinence, and baseline diseases status. The prevalence among race, age, and ethnic groups needs future research.

### Prevalence of FI in Community Dwelling Elderly Adults

Three percent ^111^ to 6 percent ^158^ of older adults living at home suffer from combined UI and FI (Table 13). The prevalence in elderly men varied substantially from 2 to 6 percent in Europe ^111^ to 39 percent in the United States. ^6^ The same prevalence of 4 to 6 percent of combined incontinence was found in European elderly women ^111^ with a rate several times higher in American females (27 percent). ^6^

Table 13 Prevalence of FI in community dwelling elderly adults

Author | Definition | Prevalence (%) | 95% CI
Sample
Men and Women
Teunissen, 2004 ^111^ | Combined UI and FI, >80 years old | 6.0 | 4.0; 8.9
N = 4,650 | Combined UI and FI, total | 3.0 | 2.6; 3.5
| FI, >80 years old | 10.0 | 7.4; 13.4
| FI, Total | 6.0 | 5.4; 6.7
| Liquid feces | 1.1
| Solid feces | 2.0
Bliss, 2004 ^158^ | Combined UI and FI | 1.7
N = 1,352 | FI | 26.3
| FI one or more times within the past year | 19
| FI daily | 1.5
| Liquid feces | 16.6
| Soils underwear | 21.6
| Solid or liquid feces | 1.97
Nakanishi, 1997 ^58^ | FI | 15.3 | 13.5; 17.3
N = 1,405
Prosser, 1997 ^603^ | FI | 9.3 | 7.1; 12.1
N = 527
Goode, 2005 ^219^ | FI | 12.0
N = 1,000
Men
Roberts, 1999 ^6^ | Combined UI and FI | 39.1 | 19.1, 59.0
N = 23 | Fecal incontinence | 3.1 | 2.9, 9.1
Teunissen, 2004 ^111^ | Combined UI and FI | 6.0 | 2.8; 11.9
N = 2,137 | Combined UI and FI | 2.0 | 1.5; 2.6
| FI | 16.0 | 10.4; 23.7
| FI | 7.0 | 6.0; 8.2
| Liquid feces | 0.6
| Solid feces | 1.9
Goode, 2005 ^219^ | FI | 12.4
N = 1,000
Women
Roberts, 1999 ^6^ | Combined UI and FI | 27.3 | 12.1; 42.5
N = 33
Teunissen, 2004 ^111^ | Combined UI and FI | 6 | 3.6; 9.7
N = 2,513 | Combined UI and FI | 4 | 3.3; 4.8
| FI | 8 | 5.1; 12.1
| FI | 6 | 5.1; 7.0
| Liquid feces | 1.5
| Solid feces | 2.1
Goode, 2005 ^219^ | FI | 11.6
N = 1,000
Bharucha, 2005 ^161^ | Moderate FI | 0.8
N = 2,800
Bradley, 2005 ^125^ | Strain with defecation | 25
N = 297

The prevalence of FI varied from 6 to 10 percent in Europe ^111,^ ^603^ to 15 percent in Japan ^58^ to 26 percent in the United States. ^158^ The prevalence of solid FI was around 2 percent in two studies, ^111,^ ^158^ while liquid FI was more than ten times higher in the American study (17 percent) ^158^ than in Europe (1 percent). ^111^ The prevalence did not show consistency in elderly males with ranges in FI from 3 percent ^6^ to 16 percent. ^219^ The prevalence of FI in elderly women averaged 6 to 8 percent in Europe ^111^ and 12 percent in the United States. ^219^

### Prevalence of FI in Community Dwelling Men

Prevalence of FI in community dwelling men varied across the studies depending on definitions of incontinence and population characteristics, including the proportion of subjects with FI only in the samples when anal or combined incontinence were analyzed.(Table 14).

Table 14 Prevalence of FI in community dwelling men

Author (Sample) | Definition | Prevalence (95% CI)
<60 Years
Roberts, 1999 ^6^ (N = 38) | Combined UI and FI | 15.8 (4.2; 27.4)
Roberts, 1999 ^6^ (N = 188) | FI | 6.9 (3.3; 10.5)
Roberts, 1999 ^6^ (N = 778) | Combined UI and FI | 5.9 (4.1; 7.6)
| FI | 11.1 (8.8; 13.5)
Walter, 2002 ^604^ (N = 758) | Flatus | 17.8 (15.3; 20.7)
| Underwear staining | 21.0 (18.2; 24.0)
Walter, 2002 ^604^ (N = 758) | Liquid feces | 0.7 (0.3; 3.4)
| Solid feces | 0.2 (0.0; 1.0)
Enck, 1991 ^605^ (N = 65) | Solid or liquid feces | 1.5 (0.3; 8.2)
| Underwear staining | 6.2 (2.4; 14.8)
Thomas, 1984 ^606^ (N = 5,975) | Solid or liquid feces | 1.0 (0.8; 1.3)
>60 Years
Roberts, 1999 ^6^ (N = 65) | Combined UI and FI | 15.4 (6.6; 24.2)
Roberts, 1999 ^6^ (N = 80) | Combined UI and FI | 25.0 (15.5; 34.5)
Roberts, 1999 ^6^ (N = 141) | FI | 12.1 (6.7; 17.5)
Roberts, 1999 ^6^ (N = 206) | FI | 5.8 (2.6; 9.0)
Roberts, 1999 ^6^ (N = 778) | FI | 11.1 (9.0; 13.5)
Teunissen, 2004 ^111^ (N = 2,137) | Combined UI and FI | 1.0 (0.5; 1.8)
| Combined UI and FI | 1.0 (0.5; 2.0)
| Combined UI and FI | 2.0 (1.0; 3.9)
| Combined UI and FI | 4.0 (2.1; 7.2)
| FI | 6.0 (4.4; 8.1)
| FI | 6.0 (4.2; 8.4)
| FI | 8.0 (4.6; 11.3)
| FI | 9.0 (5.9; 13.3)
Adolfsson, 1998 ^180^ (N = 661) | Constipation | 9.0
| Solid or liquid feces | 4.0
| Urgency | 10.0
Lopes, 1997 ^613^ (N = 43) | FI | 16.3 (8.1; 30.0)
Walter, 2002 ^604^ (N = 213) | FI | 1.0 (0.3; 3.4)
O'Keefe, 1995 ^608^ (N = 270) | FI | 8.1 (5.4; 12.0)
Diokno, 1990 ^607^ (N = 666) | FI | 5.4 (3.9; 7.4)
Thomas, 1984 ^606^ (N = 1,102) | FI | 4.1 (3.1; 5.4)
Wetle, 1995 ^50^ (N = 1,449) | FI | 8.5 (7.2; 10.0)
Edwards, 2001 ^508^ (N = 1,625) | FI | 1.0 (0.6; 1.5)
Verhagen, 2001 ^609^ (N = 3,345) | FI | 8.0 (7.1; 9.0)
Talley, 1992 ^160^ (N = 328) | FI more than once a week | 4.5 (1.3; 7.7)
| FI more than once a week | 4.6 (1.4; 7.8)
Combined Age Groups
Damon, 2006 ^623^ (N = 706) | AI | 2.4 (1.1; 4.7)
Nelson, 1995 ^622^ (N = 6,959) | AI | 0.8
Lam 1999 ^618^ (N = 259) | FI | 15.1 (11.2; 19.9)
| Flatus | 8.1 (5.4; 12.1)
Roche, 2002 ^612^ (N = 268) | FI | 3.0 (1.5; 5.8)
| Flatus | 3.0 (1.5; 5.9)
| Liquid feces | 2.6 (1.3; 5.3)
| Solid feces | 0.4 (0.1; 2.1)
Kalantar, 2002 ^217^ (N = 286) | FI | 10.8 (7.7; 15.0)
| Solid feces | 3.1 (1.7; 5.9)
| Liquid feces | 9.4 (6.6; 13.4)
MacLennan, 2000 ^7^ (N = 1,464) | FI | 2.3 (1.6; 3.2)
| Flatus | 6.8 (5.7; 8.2)
Drossman, 1993 ^610^ (N = 2,639) | FI | 0.5 (0.3; 0.8)
Perry, 2002 ^611^ (N = 4,633) | FI | 2.8 (2.4; 3.3)
| Underwear staining | 9.6 (8.8; 10.5)

Combined UI and FI were reported in 6 to 15 percent of younger men, while 7 to11 percent experienced FI in a cross-sectional, community-based study. ^6^ Less than 2 percent of younger men were incontinent with solid or liquid feces; ^604^ – ^606^ 6 percent ^605^ to 21 percent ^604^ reported stains in underwear. Older European men had combined incontinence less often (1–4 percent) ^111^ than American men (15 to 25 percent). ^6^

The prevalence of FI was consistently <10 percent in several studies of men older than 60 years ^6,^ ^50,^ ^111,^ ^508,^ ^604,^ ^606^ – ^609^ and in studies with combined age groups. ^7,^ ^217,^ ^610^ – ^612^ One Portuguese study reported the highest rate (16 percent) of FI in patients of a geriatric ambulatory service. ^613^

Pooled prevalence of FI in community dwelling men varied across the studies with a less expected fact that the addition of flatus incontinence did not increase the prevalence of AI compared to reported prevalence of FI only (Table 15).p The lowest prevalence of AI (1.6 percent) was reported in two studies with the median age of participants between 45 and 64 years. The prevalence of FI was less than 10 percent in all age groups and increased from 6.4 percent in those 45–64 years old to 9.6 percent in elderly men. The prevalence of solid feces incontinence was reported by 1.4 percent of men 45–64 years of age and by 2 percent of elderly males. The most prevalent was combined incontinence in elderly persons; 16 percent of men over 80 years experienced UI and FI.

Table 15 Pooled prevalence of AI (FI) in males by type and age categories (random effects model)

Type | Age (Studies) | Prevalence (95% CI)
AI | 45–64 years (2) | 1.6 (0.0; 3.2)
FI | 45–64 years (8) | 6.43 (4.8; 8.1)
FI | 65+ years (12) | 7.18 (5.3; 9.1)
FI | 80 and over (3) | 9.63 (4.5; 14.8)
Liquid feces | 45–64 years (3) | 3.34 (2.0; 4.7)
Solid feces | 45–64 years (3) | 1.39 (0.4; 2.4)
Solid feces | 80 and over (1) | 1.92 (1.9; 1.9)
Solid or liquid feces | 45–64 years (2) | 2.17 (<0.01; 4.3)
Solid or liquid feces | 65+ years (1) | 4 (4.0; 4.0)
FI+UI | 45–64 years (2) | 9.53 (5.4; 13.6)
FI+UI | 65+ years (2) | 8 (6.3; 9.7)
FI+UI | 80 and over (2) | 15.70 (12.0; 19.4)

### Prevalence of FI in Community Dwelling Women

Although no study investigated FI vs. AI in the same sample, there was a consistent pattern of a higher prevalence (two to four-fold) of AI than that of FI in women across age categories; this suggests that combining incontinence of flatus and feces in the same definition may contribute to increased prevalence estimates.

Less than 10 percent of females in the community experienced combined incontinence (Table 16). ^6,^ ^111,^ ^162,^ ^212,^ ^614^ Older women had higher rates of combined incontinence, but only in one study. ^6^ The prevalence of AI increased with age from 11 percent in females under 40 to 36 to 45 percent in older women. ^615^

Table 16 Prevalence of FI in community dwelling women

Author | Age | Sample Size | Prevalence (95 % CI)
Combined UI and FI
Roberts, 1999 ^6^ | 50–59 | 114 | 17.5 (10.5; 24.5)
| 60–69 | 117 | 21.4 (14.0; 28.8)
| 70–79 | 91 | 15.4 (8.0; 22.8)
| >50 | 762 | 9.4 (7.1; 11.6)
Teunissen, 2004 ^111^ | 60–64 | 2,513 | 3.0 (1.9; 4.6)
| 65–69 | | 4.0 (2.6; 6.0)
| 70–74 | | 5.0 (3.3; 7.4)
| 75–79 | | 7.0 (4.6; 10.4)
Griffiths, 2006 ^614^ | | 321 | 8.4
Ballester, 2005 ^162^ | | 115 | 9.7
Boreham, 2005 ^212^ | | 457 | 9.9
AI
Gordon, 1999 ^615^ | <30 | 9 | 11.0
Kahn, 2005 ^629^ | >18 | 1,004 | 20.0
Gordon, 1999 ^615^ | >80 | 22 | 45.0
Boreham, 2005 ^212^ | 18–65 | 457 | 28.4 (24.4; 32.8)
Gordon, 1999 ^615^ | 31–40 | 17 | 29.0
| 41–50 | 40 | 28.0
| 51–60 | 58 | 19.0
| 61–70 | 73 | 30.0
| 71–80 | 64 | 36.0
Nelson, 1995 ^622^ | | 6,959 | 1.4
Damon, 2006 ^623^ | | 706 | 7.5 (5.0; 10.7)
Gordon, 1999 ^615^ | | 283 | 29.0
Roberts, 1999 ^6^ | 50–59 | 114 | 8.8 (3.6; 14.0)
| 60–69 | 157 | 14.0 (8.6; 19.4)
| 70–79 | 105 | 10.5 (4.6; 16.4)
| >80 | 24 | 12.5 (0.0; 25.7)
Bharucha, 2005 ^161^ | <40 | 2,800 | 5.6
| <60 | | 6.7
Roberts, 1999 ^6^ | >50 | 762 | 15.2 (12.5; 17.9)
Bharucha, 2005 ^161^ | >61 | 2,800 | 5.8
Teunissen, 2004 ^111^ | 60–64 | 2,513 | 4.0 (2.8; 5.7)
| 65–69 | | 5.0 (3.5; 7.1)
| 70–74 | | 7.0 (5.0; 9.7)
| 75–79 | | 8.0 (5.4; 11.5)
Melville, 2005 ^163^ | | 3,444 | 7.2
Bharucha, 2005 ^161^ | | 2,800 | 12.1 (11.0; 13.1)
Ballester, 2005 ^162^ | | 115 | 13.6

The prevalence of FI also increased with age from 6 percent in women younger than 40 years, ^161^ to 9 percent in those 50–59 years and 13 to 18 percent in older women. ^6,^ ^42^ Association with age was found in two studies, ^6,^ ^111^ but the rates were not consistent across studies. The prevalence of FI varied by the type of incontinence (Appendix Table F6). The prevalence of flatus was less than 10 percent in the majority of the studies. ^162,^ ^205,^ ^232,^ ^604,^ ^612,^ ^613,^ ^616^ – ^618^ Only four studies reported flatus incontinence in more than 20 percent of women. ^99,^ ^125,^ ^212,^ ^619^ The prevalence of incontinence of liquid feces was less than 10 percent in 50 percent of the studies. ^163,^ ^205,^ ^604,^ ^612,^ ^616,^ ^617,^ ^619^ Few studies reported a prevalence of more than 10 percent ^125^ or 20 percent. ^99^ The prevalence of incontinence of solid and liquid feces was <10 percent in four of 12 studies that reported this outcome. ^163,^ ^508,^ ^604,^ ^606^ Most of the studies found that 5–10 percent of women were incontinent of solid and liquid feces. ^42,^ ^50,^ ^99,^ ^607^ – ^609,^ ^613^ The prevalence of solid feces was <5 percent in 10 of 15 studies that assessed this outcome. ^125,^ ^163,^ ^205,^ ^217,^ ^604,^ ^612,^ ^616,^ ^617,^ ^619,^ ^620^ Four studies found that 5–10 percent experience incontinence of solid feces. ^99,^ ^161,^ ^615,^ ^621^ Severity of FI in females increased with age (Appendix Table F7). ^161^ The prevalence of monthly FI varied from 6 percent ^162^ to 25 percent; ^125^ One percent ^162^ to 5 percent ^163^ of women had more than one FI episode per month. The prevalence of weekly FI was less than 7 percent in the majority of the studies. ^125,^ ^160,^ ^161,^ ^163^ Less than 2 percent of community dwelling women reported daily FI. ^125,^ ^161^

Pooled prevalence of AI was the highest in women compared to other definitions and increased from 22 percent to 45 percent with aging (Table 17) An inclusion of flatus incontinence in the definition contributes to increased prevalence estimates in females. Prevalence of FI was higher than in males and increased from 7 percent in those 45–60 years of age to 10 percent among elderly women. Combined UI and FI were experienced by 10 to 12 percent of women. The prevalence of monthly FI varied from 6 percent to 25 percent; 1 percent to 5 percent of women had more than one FI episode per month. The prevalence of weekly FI was less than 7 percent in four studies. Less than 2 percent of community dwelling women reported daily FI in three studies.

Table 17 Pooled prevalence of AI (FI) in females by type and age categories (random effects model)

Type | Age Categories (Studies) | Prevalence (95% CI)
Anal | 19–44 years (3) | 22.10 (16.10; 28.10)
Anal | 45–64 years (3) | 16.98 (9.61; 24.35)
Anal | 65+ years (1) | 33.00 (27.12; 38.88)
Anal | 80 and over (1) | 45.00 (44.81; 45.19)
FI | 45–64 years (5) | 7.31 (5.29; 9.32)
FI | 65+ years (3) | 8.53 (7.32; 9.75)
FI | 80 and over | 9.52 (7.26; 11.79)
Solid feces | 45–64 years (14) | 3.59 (2.75; 4.43)
Solid feces | 80 and over (1) | 2.07 (2.06; 2.08)
Liquid feces | 45–64 years (12) | 6.79 (5.15; 8.42)
Liquid feces | 80 and over (1) | 1.47 (1.47; 1.48)
Solid and liquid feces | 45–64 years (1) | 2.17 (2.16; 2.17)
Solid and liquid feces | 65+ years (10) | 7.18 (5.13; 9.24)
Solid or liquid feces | 45–64 years (18) | 5.03 (4.17; 5.89)
Flatus | 19–44 (2) | 16.28 (1.99; 34.55)
Flatus | 45–64 years (12) | 14.23 (10.73; 17.72)
FI+UI | 45–64 years (3) | 9.63 (1.67; 20.93)
FI+UI | 65+ years (2) | 10.37 (8.49; 12.24)
FI+UI | 80 and over | 12.43 (10.23; 14.62)

### Prevalence of FI in Community Dwelling Adults

Several studies did not differentiate prevalence of FI by gender (Appendix Table F8). Combined UI and FI increased with age ^111^ and varied from 1 percent to 6 percent in older adults. ^222^ The prevalence of FI was 2 percent in an American study ^622^ and 5 percent in a French study. ^623^ The prevalence of FI also increased with age and sample; ^111,^ ^159^ it varied from approximately 5 to 8 percent in a community based study ^111^ to 12–19 percent among adults visiting primary care physicians or gastroenterologists. ^159^ The prevalence of FI of liquid feces was 7 percent, ^624^ higher than FI of solid or liquid feces (3 percent ^625^ to 4 percent ^626^ ). Daily FI was reported by 3 percent of adults, ^159^ weekly FI by 4 percent ^160^ to 5 percent, ^159^ and monthly FI by 7 percent ^159^ (Appendix Table F9). Daily incontinence of solid feces was found in 0.4 percent of adults; ^627^ weekly incontinence was experienced by 0.1 percent ^623^ to 3 percent ^627^ of adults.

### Prevalence of FI in Community Dwelling Adults by Race

African American and White men had the same prevalence of FI (14 percent vs. 11 percent, respectively) (Appendix Table F10). ^219^ Prevalence of FI varied in African American women from 9 percent ^219^ to 19 percent ^628^ and in White women from 7 percent ^187^ to 21 percent, ^628^ being lowest in Asian American women (4 percent). ^187^ The prevalence of combined UI and FI was 11 percent in Asian women and 20 percent in White women. ^187^

### Limitations

Variations in definitions of FI and its severity, few population level studies with multivariate analyses, differences in samples, and inconsistency in factors adjusted in statistical modeling prevent firm conclusions; pooled estimates and meta-analysis procedures could not be conducted in many instances. Data were inconsistently reported for FI severity characteristics (frequency, amount, consistency of leakage, and duration) and analyses of associated factors were few, so knowledge is limited. Use of a standard definition of FI that excludes flatus and determination of a minimum set of variables to be collected and used in multivariate analyses are recommended.

### Summary

In conclusion, the published evidence, level IIB-III, suggests that the prevalence of FI increases with age and varies, depending on the country where studies were conducted; population-based, clinic-based, or administrative sampling of the adults; and definitions of FI with increased prevalence of AI in women but not in men.. Data were inconsistently reported for FI severity characteristics (frequency, amount, consistency of leakage, and duration), and analyses of associated factors were few, so knowledge is limited. Use of a standard definition of FI that excludes flatus and determination of a minimum set of variables to be collected and used in multivariate analyses are recommended.

Less than 10 percent of females in the community experienced combined incontinence. The prevalence of combined incontinence in men was not consistent and varied by age and residency categories. The prevalence of FI was consistently <10 percent in men of different age groups. Most of the studies found that 5 to 10 percent of women were incontinent of solid and liquid feces and <5 percent of solid feces. The prevalence of FI was the same among race categories. Heterogeneity in prevalence across studies does not allow valid pooled estimates. The primary cause for FI; risk factors, age, and gender may contribute to differences in results. Adjusted prevalence and incidence of FI should be investigated in prospective studies. Studies with older adults identified through medical records and administrative databases reported higher prevalence of FI. Differences between quantitative definitions of FI account for variation in the results. Studies of FI incidence and risk factors are greatly needed.

## Question 2. What are the Independent Contributions of Risk Factors for Urinary, Fecal, and Combined Urinary and Fecal Incontinence?

### Overview of Risk Factors for UI

Early epidemiological studies identified a number of potential risk factors of UI in a variety of adult populations (childbearing women, nonchildbearing women, men, men following prostate surgery) using univariate or bivariate analyses. In the past decade, there have been an increasing number of large population-based studies that incorporate multivariate analyses enabling the determination of the independent effect of a particular risk factor. However, the majority of studies have been cross-sectional in design which provides data only on risk factors for prevalent incontinence (Appendix F Table 1). Many of these studies are national population-based surveys on the general health of a particular population and are limited by the variables included in the study. Longitudinal studies incorporating multivariate analyses that provide data on the risk factors for incident incontinence are scarce.

In women, the major modifiable risk factors included obesity, vaginal trauma, and vaginal prolapse. Studies on risk factors such as lifestyle factors, selected chronic diseases, and medication use are limited. Inconsistencies in findings related to particular risk factors might be explained, in part, by the differences in the age of the study populations, the definition and measurement of UI, and the risk factors available for analysis. Longitudinal studies have found that risk factors for prevalent vs. incident UI vary. ^149^ In general, the risk factors for the various types of UI (stress, urge, and mixed) also vary. Aging tends to be associated with changing risk profiles associated with UI and UI type. The evidence presented next includes only those studies that incorporated multivariate analyses.

### Risk Factors for UI in Community Dwelling Women

#### Age

Age tends to be linearly associated with UI, with prevalence and incidence rates increasing steadily with advancing age. ^7,^ ^41,^ ^53,^ ^55,^ ^56,^ ^62,^ ^65,^ ^80,^ ^81,^ ^83,^ ^85,^ ^99,^ ^105,^ ^133,^ ^138,^ ^143,^ ^184^ However, in older women an increase in incidence of weekly ^123^ UI was not significant when women 75–79 years were compared to those 70–74 years of age (Appendix Table F11). The large Canadian Study of Health and Aging cohort reported no significant increase in annual incidence of UI in women 75–84 or older than 85 years compared to women younger than 75 years of age. ^186^

Prevalent UI significantly increased with age in 20 ^7,^ ^55,^ ^66,^ ^67,^ ^73,^ ^74,^ ^81,^ ^84,^ ^92,^ ^96,^ ^97,^ ^105,^ ^118,^ ^124,^ ^133,^ ^138,^ ^149,^ ^185^ – ^187^ of 28 studies that reported the association. ^7,^ ^55,^ ^62,^ ^66,^ ^67,^ ^73,^ ^74,^ ^81,^ ^84,^ ^92,^ ^93,^ ^95^ – ^97,^ ^105,^ ^118,^ ^124,^ ^132,^ ^133,^ ^138,^ ^140,^ ^144,^ ^149,^ ^185^ – ^189^ Only one population-based cross-sectional study of 5,701 female participants in the Health and Retirement Study showed a decrease of 3 percent per 1 additional year in prevalence of moderate UI with 15 or fewer days with incontinence episodes in the last month. ^189^ Adjusted odds of prevalent stress UI increased by 110 percent per 5 year incremental increase in age in participants of the Heart & Estrogen/Progestin Replacement Study ^66^ with nonsignificant dose response association in the British cohort of 12,570 female respondents older than 40 years. ^132^ The largest increase in odds of stress UI (239 percent) was reported among women over 80 years compared to those younger than 60 years ^133^ in the European population-based study of 5,795 elderly community dwelling females. ^133^

Prevalence of total weekly UI significantly increased by 106 percent per additional 1 year ^96,^ ^149^ and daily UI by 103 per additional 5 years of age. ^140^ Adjusted odds of occasional monthly UI was 1.2 and odds of severe UI 1.3 times in women 40–44 years compared to those younger than 40 years old. ^138^ Women 45–54 years old experienced UI 2.1 times more often and those older than 55 years of age 3.1 time more often than those 15–34 years old. ^7^ Odds of reporting any UI was 3.7 times greater in women 50–59 than those 41–49 years old. ^84^ Women older than 70 years experienced UI 1.49 ^81^ to 2.9 times ^84^ more often than women under 50. The dose response association with severity of UI was shown in the Nurses' Health Study with odds ratio 1.45 for occasional, 1.56 for occasional severe, 1.67 for frequent and severe, and 1.81 for weekly severe UI in women older than 70 compared to those under 50. ^84^ Women 75–84 years old had 1.47 ^186^ to 6.7 ^92^ times higher odds of UI compared to women under 75 years and those 15–24 years old, respectively.

Adjusted prevalence rates of weekly urge UI increased by 1.2 ^66^ per 5 additional years of age and by 1.8 times ^187^ per 10 additional years of age in a dose response model. Monthly urge UI was 1.8 time more frequent ^133^ among women 60–80 years old than for those under 60. Elderly women older than 80 years reported monthly UI four times more often than women younger than 60. ^133^ One community base Japanese survey of 968 women older than 40 years reported lower odds of urge UI among those older than 60. ^74^

Maternal age at the time of either the first or last delivery has been examined as a risk factor for subsequent UI; however, the effect age has on the development of UI appears to lessen by age 50. ^630^ Several studies have found that age 35 years or older at first delivery increased the risk of UI or frequent UI when compared to younger women. ^105,^ ^197^ Similarly, one study found a lower risk in women who were 25 years or younger at their first delivery than their older counterparts (23 percent vs. 28 percent, respectively). ^630^ Another study found that being age 30 or more at the second delivery doubled the odds of becoming incontinent. ^197^ Two studies reported that the strongest associations with UI were for women who were under the age of 22 years at their first delivery. ^105,^ ^135^ In one study examining maternal age at subsequent deliveries, women older than 30 and 40 years at a second vaginal delivery had lower rates of UI and urge UI. ^64^ Other studies have not been able to demonstrate an independent effect of age on UI in the immediate postpartum period. ^198^ Age at last delivery appears to be less of a risk factor. ^630^

#### Gender

Female gender has been consistently documented as a strong predictor of UI in bivariate analyses, ^30,^ ^36,^ ^39,^ ^47,^ ^61,^ ^74,^ ^92,^ ^97,^ ^107,^ ^114^ with an age-adjusted odds of UI of 3.1. ^92^ One in six women after age 30 have UI, compared to 1 in 20 men. ^587^ Women have higher rates of UI than men in all age groups. ^81,^ ^86^ In early adult years, women have a two to four times higher rate of UI than men; however, in advanced years (e.g., ages 75 or 85 and over), even though women continue to have higher rates, the prevalence rates are more similar. ^81^ In a study of 54,920 adults ≥30 years, the UI rate in women was 2.5 per 100 versus 1.4 per 100 in men. ^86^ Other studies find that UI prevalence is 6.8 times higher in women. ^75^

#### Race/Ethnicity

There is growing evidence that race/ethnicity is a predictor of UI, UI severity, and UI type in nonchildbearing and childbearing women (Appendix Table F12). In earlier studies, White women tended to have higher rates of UI than other ethnic/racial groups (Blacks, Asian Americans, including Japanese and Chinese, and Hispanics). ^30,^ ^59,^ ^89,^ ^93,^ ^105,^ ^120,^ ^138^ In more recent studies, being non-White was associated with lower odds of having UI and severe UI, ^144^ with the exception of being Hispanic. ^138^ A higher UI incident rate in Whites was reported in two studies (OR 3.1, 95 percent CI 2; 4.8) (Figure 3). ^123,^ ^149^ African American women had higher odds of incident urge but lower odds of incident stress UI. Hispanic women developed weekly UI more often compared to Caucasian (OR 2.96, 95 percent CI 1.06; 8.18).

Figure 3. Association between incident UI in women of different races compared to Caucasian women (results from two studies) ^123,^ ^149^

Prevalence of mild, moderate, and severe UI was lower among African American women than White women in all six studies that examined the association (Figure 4). ^93,^ ^105,^ ^137,^ ^138,^ ^149,^ ^189^ Prevalence of moderate UI was lower among Hispanic women compared to Caucasian women in four of five studies (Figure 5). ^93,^ ^105,^ ^138,^ ^149,^ ^189^ However, evidence was not consistent. Prevalence of mild or severe UI was either less or the same in Hispanic women than in White women. Asian women had lower odds of moderate or severe UI (Appendix Figure F1) in two studies. ^105,^ ^138^

Figure 4. Prevalent UI in African American women compared to Caucasian women

Figure 5. Prevalent UI in Hispanic women compared to Caucasian women

Race/ethnicity was associated with different types of UI, including stress, urge, or mixed UI (Appendix Table F12). After multiple adjustments, the risk of stress UI was higher in White women than in Black and Asian American women. ^118,^ ^137^ In one study White women had a 2.8 times higher risk of stress UI than Black women. ^66^ In contrast, the risk of urge UI was similar in Black and Asian American women compared to White women. ^59^ In other studies, White women had three times the risk of Black women with respect to urge UI. ^118^

#### Obesity

Obesity has been consistently established as a strong predictor of UI, especially severe UI (Appendix Table F13). Incident monthly UI was 110 percent higher and daily 112 percent higher per one unit increase in BMI. ^149^ Obese females developed monthly UI 1.7 times more often (95 percent CI 1.2; 2.5) than women with normal weight. ^103^

Prevalent urge UI showed a positive dose response association 1.1 times per one unit increase in BMI, ^51^ (OR 1.08, 95 percent CI 1.1; 1.1), 1.4 times in women with BMI 25–30 than <25 kg/m^2^, ^133^ and 1.8 times (OR 1.8 95 percent CI 1.4; 2.4) in those with BMI >30 kg/m2. ^133^ Asian overweight women experienced urge UI three times more often than those with normal weight (OR 3.4, 95 percent CI 1.2; 9.2). ^187^

The largest increase in stress UI was shown in obese women with uterovaginal prolapse compared to normal weight females without prolapse (OR 33.0, 95 percent CI 12.5; 87.1). ^95^ In contrast, underweight women after surgery for UI reported stress UI more often than females with greater BMI. ^631^ Severe UI was more prevalent in overweight women (BMI 25–29kg/m^2^ OR 1.5, 95 percent CI 1.4; 1.6) and obese women (BMI >30 OR 3.1, 95 percent CI 2.9; 3.3). ^138^

The effect of BMI differed depending on definitions of UI (Figure 6). Odds of ever having UI were higher in underweight and overweight women. ^116,^ ^191^ Adjusted odds of UI in the past month were higher in overweight and obese females. ^83,^ ^92,^ ^133,^ ^143^ Weekly UI was more prevalent in obese but not overweight women with a dose response increase per one unit of BMI. ^66,^ ^90,^ ^92,^ ^96,^ ^138,^ ^189^ With the definition of UI in the past year (Figure 7), the majority of the studies showed a significant increase in UI corresponding to greater BMI. ^7,^ ^51,^ ^59,^ ^68,^ ^72,^ ^144^

Figure 6. Association between prevalent UI and BMI in women depending on time of having UI

Figure 7. Association between prevalent UI and BMI in women who reported involuntary urine loss in the past year

The association between BMI and UI varied depending on frequency of leakage episodes (Figure 8) The majority of the studies reported a significant raise in daily UI corresponding to an increase in BMI per one unit (OR 1.44, 95 percent CI 1.3; 1.6), per five units (OR 1.6, 95 percent CI 1.4; 1.7), or in overweight women (OR 1.65, 95 percent CI 1.3; 2.1). ^55,^ ^67,^ ^70,^ ^149,^ ^189^ Incremental increase per one unit in BMI was not associated with higher adjusted rates of at least monthly UI; however, obese women had greater odds of UI compared to women with normal weight. ^67,^ ^104,^ ^121,^ ^124,^ ^138,^ ^149,^ ^190^ Underweight and obese women had increased odds of having at least weekly UI. ^67,^ ^92,^ ^138,^ ^185^ Daily and weekly stress UI were significantly associated with an increase in BMI in all studies (Figure 9). ^51,^ ^66,^ ^70,^ ^118,^ ^132,^ ^133,^ ^135,^ ^149,^ ^187^ The association with UI at least monthly or in the past year was less consistent.

Figure 8. Association between severity of prevalent UI and BMI in women

Figure 9. Association between severity of prevalent stress UI and BMI in women

Studies in older women have found that a higher BMI (OR 1.3 per 5kg/m^2^, CI 1.1; 1.6) was associated with stress UI but not urge UI. ^118^ Other studies found that increasing BMI was associated with urge UI in women ages 40–60 years, whereas one study did not find an association. ^66^

Some studies have incorporated alternative anthropomorphic measures such as waist circumference, visceral fat area measured by computed tomography scan of the abdomen, and sagittal diameter ^66,^ ^118,^ ^149^ with mixed outcomes (Appendix Table F14). One study found that waist to hip ratio was predictive of stress UI. ^66^ Other studies found increasing waist circumference is weakly associated with prevalent mixed UI (OR 1.0, 95 percent CI 1.0; 1.1 per 1cm increase in waist circumference), stress UI (OR 1.0, 95 percent CI 1.0; 1.1), and total monthly UI (OR 1.1, 95 percent CI 1.0; 1.1). ^149^

Evidence on maternal weight and maternal weight gain during pregnancy is conflicting. In one study, women with higher BMIs (>25kg/m^2^) and higher maternal BMIs (during pregnancy) increased their odds by 168 percent in developing UI at 3 months postpartum as compared to women with lower BMIs. ^197^ In another study, higher predelivery BMI (per 5kg/m^2^) increased the odds of UI at 6 months postpartum by 20 percent. ^203^ In other studies, maternal weight gain was not associated with UI ^199^ or the development of stress UI 10 years after the index delivery. ^196^

#### Genetic influence

Evidence from four studies suggests a genetic influence on UI. ^632^ – ^635^ In one study, daughters of mothers with stress UI had a higher prevalence of stress UI than age-matched controls, 71.4 percent versus 40.3 percent, respectively. ^632^ Furthermore, UI symptoms appeared 7 years earlier in “incontinent families” than in those without a history of incontinence. ^632^ In a case-control study examining relatives of women with urodynamically diagnosed UI, first-degree relatives had a UI prevalence of 20.3 percent versus 7.8 percent in relatives of the control group. ^635^ Both mothers and sisters had significantly higher prevalence rates of stress UI than controls. Although daughters had a UI prevalence rate twice as high as controls, the difference was not significant. ^635^ In a population-based study, daughters of mothers with any type of UI had a 1.3 times higher risk of being incontinent, (95 percent CI 1.2; 1.4), a 1.5 times higher risk (95 percent CI 1.3; 1.8) of stress UI and 1.8 times higher risk (95 percent CI 0.8; 3.9) of urge UI. ^633^ Daughters were also at higher risk of having severe incontinence if the mother had severe incontinence (1.9; 95 percent CI 1.3; 3.0). ^633^ Younger sisters of female siblings with UI, stress UI, or mixed UI had increased relative risks, respectively of 1.6 (95 percent CI 1.3; 1.9), 1.8 (95 percent CI 1.3; 2.3), and 1.7 (95 percent CI 1.1; 2.8). ^633^ In another population-based study involving 548 monozygotic and 620 dizygotic twin pairs, the heritability for urge UI was 42 percent (95 percent CI 16; 63) among women ages 48–64 years and 49 (95 percent CI 29; 65) in those ages 70–94 years. ^634^ Mixed UI also had a substantial genetic component; however, the role of genetic factors was less clear. ^634^

### Lifestyle Factors

#### Physical activity

There is limited data on the role of physical activity as a risk factor for UI (Appendix Table F14). Intensive physical activity in women 50–79 years of age in the Nurses' Health Study was associated with a significant reduction in incident UI (OR 0.9, 95 percent CI 0.8; 1.0). ^156^ Physically active women developed stress UI less frequently (OR 0.71, 95 percent CI 0.56; 0.91). ^156^ The same study reported a significant negative association between walking and incident urge UI (OR 0.7, 95 percent CI 0.5; 0.9). ^156^

In a large study of women ≥20 years, after adjusting for age, number of children, coughing, and wheezing/dyspnea, increasing levels of low physical activity had weak and negative associations with UI. ^192^ No significant effects were noted for high intensity physical activity with respect to stress, urge, and mixed UI. Similarly, a large study of women ≥40 years did not find an effect for those with different levels of physical activity or participating in vigorous activities. ^103^ In a study examining the impact of physical activity on urine leakage in 665 primiparous women, high impact exercise before pregnancy was significantly associated with UI 1 year after childbirth, increasing the odds of UI by 40 percent. ^636^ In two surveys, physical exercise in the past year was not associated with UI. ^55,^ ^83^

#### Education and occupational status

Studies on occupational factors and UI risk are rare. In a study involving 1,581 Taiwanese women ≥20 years, having an occupation that involved weight lifting or other labor was not significantly associated with stress UI. ^95^ Women without private health insurance had higher adjusted odds of urinary symptoms (OR 2.6, 95 percent CI 1.4; 5). ^84^

Surprisingly, higher education was associated with increased odds of prevalent UI in the majority of the studies. ^67,^ ^70,^ ^72,^ ^83,^ ^93,^ ^149,^ ^189,^ ^191^ College graduates 42–52 years old experienced UI 1.31 times more often compared to women without degrees; ^93^ university graduates 50–64 years old reported UI 2 times more often (OR 2.0; 95 percent CI 1.8; 2.3) ^191^ than females with lower education. One study found that higher education was an independent risk factor for UI for all ethnic groups except Chinese Americans but that educational level was not associated with moderate/severe UI. ^93^ However, in contrast to these studies, one study of postpartum incontinence reported that having less than a college education doubled the risk of UI. ^203^

#### Marital status and social support

Married women had the same prevalence of UI as women who were widowed, divorced, or never married. ^84^ A large Study of Women's Health Across the Nation ^149^ suggested no association between level of social support and incident monthly UI. However, the same cohort reported higher prevalence rates of UI among women within the lower quartile of social support. ^149^ Psychological stress was associated with greater urinary symptoms including UI (OR 2.7, 95 percent CI 1.1; 7) ^84^ but not with UI in the past month. ^83^ Low social activity was not associated with risk of stress, urge, or mixed UI in women ≥70 years. ^106^ The interpretation of whether decreased social activity and poor social support precipitates UI or is a result of UI is unclear.

#### Dietary factors

##### Caffeine

Evidence of caffeine consumption as a risk factor for UI is limited and conflicting. In a Norwegian study of 34,755 women ≥20 years of age, coffee consumption (number of cups/day) was not associated with UI in a multivariate analysis, whereas tea drinkers were at a slightly higher risk for all types of UI. (Appendix Table F15). ^192^ In other studies, coffee consumption has either not been associated with UI risk ^55,^ ^103^ or was shown to reduce the odds by 50 to 60 percent, depending on the amount consumed. ^72^ One large study in the United Kingdom did not find an association between tea consumption and UI risk. ^103^

##### Carbonated beverages

Data on the type and amount of beverages consumed is scarce. In one study involving 6,424 women, daily consumption of carbonated beverages increased the odds of stress UI in women ≥40 years by 62 percent. ^103^ Although this study also examined the effect of carbonated beverages in women with overactive bladder, it was not possible to determine the effect in those who had urge UI alone.

##### Food consumption

Only one study has examined the role of different food groups on the risk of stress UI. ^103^ Consumption of various amounts of vegetables and chicken were not associated with stress UI, whereas eating bread daily or more was associated with decreasing the odds of stress UI by 24 percent. ^103^

##### Alcohol use

Few studies have examined the effect of alcohol consumption on UI. ^55,^ ^67,^ ^72,^ ^83,^ ^84,^ ^92,^ ^190^ Some studies that did examine alcohol use, including the type of alcohol consumed, did not include it in a multivariate analysis. ^103,^ ^118^ Alcohol consumption, as measured by number of glasses of alcoholic beverages consumed over a two-week period and the number consumed each week, has not been found to be a risk factor for UI. ^55,^ ^72,^ ^83,^ ^192^ Only one study reported a greater odds of weekly UI among women with daily alcohol use compared to never drinkers. ^83^ Women with low and moderate alcohol consumption had lower adjusted rates of occasional UI. ^190^

#### Smoking

Smoking as a risk factor for UI has been assessed in several studies. ^55,^ ^72,^ ^83,^ ^93,^ ^103,^ ^118,^ ^138,^ ^192^ (Appendix Table F16). Six studies ^92,^ ^93,^ ^138,^ ^186,^ ^189,^ ^192^ of 12 ^67,^ ^72,^ ^83,^ ^92,^ ^93,^ ^138,^ ^143,^ ^186,^ ^189,^ ^191,^ ^192^ found a significant positive association between smoking and UI. One study suggests that smoking status per se is not associated with UI, but rather examining the dose-response relationship between numbers of cigarettes smoked, either as a former or current smoker, may be more relevant. ^192^ In this study both former and current smoking was associated with UI, but only for those who smoked more than 20 cigarettes per day, raising the odds of UI by 2.7 and 3.0, respectively. ^192^ However, severe incontinence was weakly associated with smoking, regardless of number of cigarettes. Interestingly, adjusted odds of current smokers in the same study ^192^ had higher odds of mixed and total but significantly lower odds of stress UI. Neither smoking status nor a dose response between numbers of cigarettes smoked per day was found to be a risk factor in a survey involving 2,767 Italian women. ^72^ Although a survey of 1,262 women in the United Kingdom found that the number of cigarettes was not associated with UI, being a former smoker did increase the odds by 30 percent. ^83^ In a large study of 83,355 American women ages 37–54 years, former smoking was not associated with UI, whereas current smoking was significantly associated with frequent and severe UI. ^138^ Current smoking increases the odds of moderate/severe UI by 20–55 percent. ^93,^ ^138^ Smoking during pregnancy independently increased the odds of UI by 290 percent (odds ratio 2.9, 95 percent CI 1.4; 3). ^198^

#### Functional status

##### Cognitive function

Studies on the role of cognitive function as a predictor of UI in community dwelling women are scarce (Appendix Table F17). The prospective Canadian Study of Health and Aging did not find a significant association between impaired cognitive function and incident UI in elderly community dwelling women. ^186^ However, another prospective study, Study of Osteoporotic Fractures, reported an increase in odds of developing UI by 1.3 times (OR 1.3, 95 percent CI 1.1; 1.6) among older women with decline in walking speed, by 1.4 times (OR 1.4, 5 percent CI 1.2; 1.6) among those with decline in chair stand speed, and by 1.6 times in females with reduced Mini-Mental State Examination scores (OR 1.6, 95 percent CI 1.1; 2.1). ^147^

Prevalence of UI was higher by 166 percent in frail community dwelling elderly with impaired cognitive status (OR 1.7, 95 percent CI 1.3; 2.1), who were participants in the Italian Silver Network Home Care project. ^97^ However, the Canadian Study of Health and Aging did not find a significant association between cognitive decline and prevalent UI. ^186^ In a survey of adults ≥75 years, memory problems significantly increased the odds of UI by 70 percent. ^114^ One study found that memory difficulties significantly increased the odds of having stress UI in a cross-sectional analysis but not in a longitudinal analysis at 1 year. ^132^

##### Depression

An increasing number of studies are examining depression as a risk factor for UI (Appendix Table F17). ^59,^ ^90,^ ^106,^ ^118,^ ^191^ Postmenopausal women with depressive symptoms developed UI 2.7 time more often (OR 2.7, 95 percent CI 1.4; 5.3) during 2 years of followup in a prospective cohort study. ^123^ The association was random in another large cohort of the Study of Women's Health Across the Nation with 6 years of followup. ^149^

Prevalence of UI was significantly higher in depressed women in five studies ^90,^ ^124,^ ^149,^ ^189,^ ^191^ of eight ^90,^ ^97,^ ^106,^ ^118,^ ^124,^ ^149,^ ^189,^ ^191^ that examined the association in multivariate analysis. The largest increase in adjusted odds of UI was observed in women with current depression (OR 2.0, 95 percent CI 1.2; 7.6) ^90^ or current major depression (OR 2.5, 95 percent CI 1.7; 3.7). ^124^ Some studies indicated that depressive symptoms are a risk factor for a particular type of UI rather than UI in general. Depressive symptoms have been strongly associated with urge UI in some studies, raising the risk by 2.7 times in women ages 70–79 years. ^118^

##### Physical function

Decreased physical function measured by self report and physical performance tests has been consistently documented as a strong predictor for UI in six studies ^67,^ ^81,^ ^92,^ ^97,^ ^144,^ ^189^ of eight ^67,^ ^81,^ ^92,^ ^97,^ ^106,^ ^132,^ ^144,^ ^189^ that examined this association (Appendix Table F17). Poor mobility increased the odds of UI by 4.7 times in women over the age of 60 ^42^ and in other studies mobility limitations, including difficulty walking, increased the odds of UI ranging from 23 to 81 percent in older women. ^81,^ ^114^

ADL impairments strongly increase the risk of UI and UI types, although findings vary. Physical impairment was associated with increased odds of stress UI by 40 to 70 percent, except in the worst level of functioning, where it was not significantly associated.132 However, in another study, it was not associated with stress UI but strongly associated with urge UI.98 In a study of women ages 55–75 years, lower scores on the SF-36 physical function scale were significantly associated with any and severe UI.144 In another study involving women ≥65 years, ADL disability increased the odds of UI by 175 percent.81 The strongest association was reported in the national health survey in Belgium with increased prevalence of UI by 415 percent (OR 4.2, 95 percent CI 1.9; 6.0) in women with moderate physical limitations and by 521 percent (OR 5.2; 95 percent CI 1.2; 8.6) among those with severe physical limitations. ^92^

Decreased physical performance measured with an objective Health ABC Performance Scale (performance on repeated chair stands, gait speed, standing balance, and a narrow walk test of balance), was associated with urge UI (OR 1.6 per point on 0–4 scale, 95 percent CI 1.1; 2.3), whereas it was not associated with stress UI. ^118^ Muscle strength as measured by grip and quadriceps strength was not associated with daily UI; however, faster gait speed (OR 0.8 per 2 units, 95 percent CI 0.6; 1.0) was associated with decreased incontinence. ^55^

The variability in populations, definitions, and measurement of UI and functional status contributed to the differences in the results from individual studies.

### Gynecological Factors

#### Parity

We identified 24 observational studies that reported odds ratios of UI in association with parity (Table 18). ^55,^ ^59,^ ^64,^ ^68,^ ^70,^ ^72,^ ^83,^ ^92,^ ^93,^ ^95,^ ^96,^ ^105,^ ^119,^ ^124,^ ^133,^ ^135,^ ^138,^ ^149,^ ^185,^ ^191,^ ^193^ – ^196^ Incident UI was not associated with parity. ^149,^ ^193^ A positive significant association between prevalent UI and parity was reported in 13 studies, ^68,^ ^72,^ ^83,^ ^93,^ ^96,^ ^105,^ ^119,^ ^124,^ ^138,^ ^185,^ ^191,^ ^193,^ ^195^ while six studies did not find a significant increase in prevalent UI in relation to parity (Figure 10). ^59,^ ^64,^ ^92,^ ^133,^ ^149,^ ^194^ The number of births did not show a dose response association with prevalent UI (odds ratio per one additional birth 1.0, 95 percent CI 1.0; 1.1) but did with moderate severe UI (odds ratio per one additional birth 1.1, 95 percent CI 1.0; 1.1) and severe UI (odds ratio per one additional birth 1.1, 95 percent CI 1.0; 1.1). All six studies that measured prevalent stress UI reported a significant positive association with parity (Figure 11). ^72,^ ^95,^ ^133,^ ^149,^ ^195,^ ^196^ Prevalent stress UI and severe stress UI did not show a significant dose response association with the number of births. Only one study ^195^ of four ^72,^ ^133,^ ^195,^ ^196^ found an increase in urge UI corresponding to parity.

Table 18 Association between parity and UI in females

Author | Incontinence | Parity | OR (95% CI)
Brown, 1996 ^55^ | Daily UI | Number of live births >2 vs. 1 | 1.2 (1.0; 1.6)
Thom 1997 ^59^ | UI | Parity 2 | 1.4 (0.5; 2.1)
| | Parity 3 | 1.5 (0.7; 2.9)
| | Parity 4 | 1.5 (0.9; 2.7)
Chiarelli, 1999 ^68^ | UI | Once vs. never | 2.82 (2.37; 3.35)
| | Twice vs. never | 2.59 (1.86; 3.61)
| | Three or more vs. never | 4.84 (2.54; 9.20)
Kuh, 1999 ^70^ | Severe incontinence | Number of children | 1.2 (0.99, 1.5)(
Bortolotti, 2000 ^72^ | Total UI | Parity 0 | 1 (1; 1)
| | Parity 1 | 1.3 (0.7; 2.4)
| | Parity 2 | 1.9 (1; 3.3)
| | Parity >3 | 2.2 (1.2; 4)
| Stress UI | Parity 0 | 1
| | Parity 1 | 3.9 (1.6; 9.5)
| | Parity 2 | 3.9 (1.7; 9)
| | Parity >3 | 3.7 (1.5; 9.1)
| Urge UI | Parity 0 | 1
| | Parity 1 | 0.2 (0.2; 3.1)
| | Parity 2 | 0.8 (0.4; 5)
| | Parity >3 | 1.5 (0.4; 5.3)
| Mixed | Parity 0 | 1
| | Parity 1 | 0.2 (0.1; 0.8)
| | Parity 2 | 0.8 (0.3; 1.9)
| | Parity >3 | 1.5 (0.6; 3.3)
Rortveit 2001 ^195^ | Total UI | Parity 0 | 1
| | Parity 1 | 1.6 (1.5; 1.8)
| | Parity 2 | 1.8 (1.6; 1.9)
| | Parity 3 | 2 (1.8; 2.2)
| | Parity >4 | 2.3 (2.1; 2.5)
| Stress UI | Parity 0 | 1
| | Parity 1 | 1.9 (1.6; 2.2)
| | Parity 2 | 2.3 (2.0; 2.6)
| | Parity 3 | 2.4 (2.1; 2.7)
| | Parity >4 | 2.3 (2.0; 2.7)
| Urge UI | Parity 0 | 1
| | Parity 1 | 1.2 (0.9; 1.6)
| | Parity 2 | 1 (0.8; 1.3)
| | Parity 3 | 1.1 (0.9; 1.5)
| | Parity >4 | 1.5 (1.2; 1.9)
| Mixed UI | Parity 0 | 1
| | Parity 1 | 1.5 (1.2; 1.8)
| | Parity 2 | 1.7 (1.4; 1.9)
| | Parity 3 | 2.1 (1.8; 2.5)
| | Parity >4 | 2.8 (2.4; 3.3)
| UI | 20–34 years old Parity 0 | 1
| | 20–34 years old Parity 1 | 2.2 (1.8; 2.6)
| | 20–34 years old Parity 2 | 2.4 (2.0; 2.8)
| | 20–34 years old Parity 3 | 2.4 (2.0; 3.0)
| | 20–34 years old Parity >4 | 3.3 (2.4; 4.4)
| Stress | 20–34 years old Parity 0 | 1
| | 20–34 years old Parity 1 | 2.7 (2.0; 3.5)
| | 20–34 years old Parity 2 | 3.4 (2.7; 4.4)
| | 20–34 years old Parity 3 | 3.6 (2.7; 4.8)
| | 20–34 years old Parity >4 | 4 (2.5; 6.4)
| Urge | 20–34 years old Parity 0 | 1
| | 20–34 years old Parity 1 | 1.7 (1.1; 2.8)
| | 20–34 years old Parity 2 | 1 (0.6; 1.7)
| | 20–34 years old Parity 3 | 1.2 (0.6; 2.3)
| | 20–34 years old Parity >4 | 1 (0.2; 4.1)
| Mixed | 20–34 years old Parity 0 | 1
| | 20–34 years old Parity 1 | 1.9 (1.4; 2.7)
| | 20–34 years old Parity 2 | 2.3 (1.7; 3.1)
| | 20–34 years old Parity 3 | 1.7 (1.1; 2.6)
| | 20–34 years old Parity >4 | 4 (2.3; 7.0)
| UI | 35–44 years old Parity 0 | 1
| | 35–44 years old Parity 1 | 1.4 (1.1; 1.9)
| | 35–44 years old Parity 2 | 1.5 (1.2; 1.9)
| | 35–44 years old Parity 3 | 1.6 (1.3; 2.1)
| | 35–44 years old Parity >4 | 1.6 (1.2; 2.2)
| Stress | 35–44 years old Parity 0 | 1
| | 35–44 years old Parity 1 | 1.9 (1.2; 2.9)
| | 35–44 years old Parity 2 | 2.2 (1.5; 3.2)
| | 35–44 years old Parity3 | 2.4 (1.6; 3.6)
| | 35–44 years old Parity >4 | 2.1 (1.4; 3.2)
| Urge | 35–44 years old Parity 0 | 1
| | 35–44 years old Parity 1 | 1.3 (0.5; 3.5)
| | 35–44 years old Parity 2 | 1.1 (0.5; 2.5)
| | 35–44 years old Parity 3 | 1.1 (0.5; 2.6)
| | 35–44 years old Parity >4 | 1.8 (0.7; 4.6)
| Mixed | 35–44 years old Parity 0 | 1
| | 35–44 years old Parity 1 | 1 (0.6; 1.7)
| | 35–44 years old Parity 2 | 1 (0.6; 1.5)
| | 35–44 years old Parity 3 | 1.1 (0.7; 1.7)
| | 35–44 years old Parity >4 | 1.2 (0.8; 2.0)
| UI | 45–54 years old Parity 0 | 1
| | 45–54 years old Parity 1 | 1.7 (1.3; 2.2)
| | 45–54 years old Parity 2 | 1.6 (1.3; 2.1)
| | 45–54 years old Parity 3 | 1.7 (1.3; 2.2)
| | 45–54 years old Parity >4 | 2 (1.5; 2.6)
| Stress | 45–54 years old Parity 0 | 1
| | 45–54 years old Parity 1 | 1.5 (1.0; 2.2)
| | 45–54 years old Parity 2 | 1.7 (1.2; 2.3)
| | 45–54 years old Parity 3 | 1.5 (1.1; 2.1)
| | 45–54 years old Parity >4 | 2 (1.4; 2.8)
| Urge | 45–54 years old Parity 0 | 1
| | 45–54 years old Parity 1 | 1.5 (0.6; 3.8)
| | 45–54 years old Parity 2 | 1.1 (0.5; 2.5)
| | 45–54 years old Parity 3 | 1.1 (0.5; 2.5)
| | 45–54 years old Parity >4 | 0.8 (0.3; 2.2)
| Mixed | 45–54 years old Parity 0 | 1
| | 45–54 years old Parity 1 | 2 (1.1; 3.5)
| | 45–54 years old Parity 2 | 1.5 0.9; 2.6)
| | 45–54 years old Parity 3 | 2.3 (1.4; 3.8)
| | 45–54 years old Parity >4 | 2.4 (1.4; 4.1)
| UI | 55–64 years old Parity 0 | 1
| | 55–64 years old Parity 1 | 1.9 (1.4; 2.7)
| | 55–64 years old Parity 2 | 1.6 (1.2; 2.1)
| | 55–64 years old Parity 3 | 1.8 (1.3; 2.4)
| | 55–64 years old Parity >4 | 1.9 (1.4; 2.6)
| Stress | 55–64 years old Parity0 | 1
| | 55–64 years old Parity 1 | 1.9 (1.2; 3.1)
| | 55–64 years old Parity 2 | 1.2 (0.8; 1.9)
| | 55–64 years old Parity 3 | 1.5 (1.0; 2.2)
| | 55–64 years old Parity >4 | 1.3 (0.9; 2.0)
| Urge | 55–64 years old Parity 0 | 1
| | 55–64 years old Parity 1 | 0.7 (0.2; 2.5)
| | 55–64 years old Parity 2 | 1.1 (0.4; 2.6)
| | 55–64 years old Parity 3 | 1.2 (0.5; 2.8)
| | 55–64 years old Parity >4 | 1.2 (0.5; 2.7)
| Mixed | 55–64 years old Parity 0 | 1
| | 55–64 years old Parity 1 | 2.8 (1.3; 6.2)
| | 55–64 years old Parity 2 | 3.1 (1.5; 6.3)
| | 55–64 years old Parity 3 | 3.4 (1.7; 6.8)
| | 55–64 years old Parity >4 | 4.6 (2.3; 9.2)
| UI | 65–74 years old Parity 0 | 1
| | 65–74 years old Parity 1 | 0.9 (0.7; 1.2)
| | 65–74 years old Parity 2 | 0.9 (0.8; 1.2)
| | 65–74 years old Parity 3 | 1.1 (0.9; 1.3)
| | 65–74 years old Parity >4 | 1.1 (0.9; 1.3)
| Stress | 65–74 years old Parity 0 | 1
| | 65–74 years old Parity 1 | 0.8 (0.5; 1.3)
| | 65–74 years old Parity 2 | 0.8 (0.6; 1.2)
| | 65–74 years old Parity 3 | 0.8 (0.6; 1.2)
| | 65–74 years old Parity >4 | 1.1 (0.8; 1.5)
| Urge | 65–74 years old Parity 0 | 1
| | 65–74 years old Parity 1 | 0.8 (0.4; 1.7)
| | 65–74 years old Parity 2 | 1.3 (0.7; 2.2)
| | 65–74 years old Parity 3 | 1.1 (0.6; 2.0)
| | 65–74 years old Parity >4 | 1 (0.5; 1.7)
| Mixed | 65–74 years old Parity 0 | 1
| | 65–74 years old Parity 1 | 1 (0.7; 1.5)
| | 65–74 years old Parity 2 | 1 (0.7; 1.4)
| | 65–74 years old Parity 3 | 1.3 (0.9; 1.8)
| | 65–74 years old Parity >4 | 1.2 (0.9; 1.6)
| UI | >75 years old Parity 0 | 1
| | >75 years old Parity 1 | 0.9 (0.7; 1.1)
| | >75 years old Parity 2 | 1.1 (0.9; 1.3)
| | >75 years old Parity 3 | 1.1 (0.9; 1.3)
| | >75 years old Parity >4 | 1.2 (1.0; 1.4)
| Stress | >75 years old Parity 0 | 1
| | >75 years old Parity 1 | 0.8 (0.5; 1.4)
| | >75 years old Parity 2 | 1.1 (0.8; 1.6)
| | >75 years old Parity 3 | 1.1 (0.8; 1.6)
| | >75 years old Parity >4 | 1 (0.7; 1.5)
| Urge | >75 years old Parity 0 | 1
| | >75 years old Parity 1 | 1.1 (0.6; 1.8)
| | >75 years old Parity 2 | 0.8 (0.5; 1.2)
| | >75 years old Parity 3 | 0.8 (0.5; 1.3)
| | >75 years old Parity >4 | 0.9 (0.6; 1.5)
| Mixed | >75 years old Parity 0 | 1
| | >75 years old Parity 1 | 0.8 (0.5; 1.3)
| | >75 years old Parity 2 | 1.2 (0.9; 1.7)
| | >75 years old Parity 3 | 1.3 (0.9; 1.8)
| | >75 years old Parity >4 | 1.5 (1.1; 2.0)
Schmidbauer 2001 ^83^ | UI | Parity 0 | 1
| | Parity 1 | 1.36 (1.0; 1.83)
| | Parity 2 | 1.38 (1.05; 1.82)
Sampselle, 2002 ^93^ | UI | Parous | 1.62 (1.31; 2.01)
Van Oyen, 2002 ^92^ | UI | Number of children vs.0 | 1
| | Number of children 1 vs.0 | 2.24 (0.95; 5.27)
| | Number of children 2 vs.0 | 1.8 (0.75; 4.32)
| | Number of children 3 vs.0 | 1.12 (0.36; 3.45)
| | Number of children 4 vs.0 | 1.99 (0.64; 6.12)
Grodstein 2003 ^105^ | Occasional leaking urine | Parity 0 | 1
| | Parity 1 | 1.14 (1.02; 1.28)
| | Parity 2 | 1.26 (1.14; 1.38)
| | Parity 3 | 1.31 (1.19; 1.44)
| | Parity 4 | 1.39 (1.26; 1.53)
| | Parity 5+ | 1.43 (1.29; 1.58)
| At least enough to wet underwear | Parity 0 | 1 (1)
| | Parity 1 | 1.14 (0.99; 1.32)
| | Parity 2 | 1.23 (1.09; 1.39)
| | Parity 3 | 1.33 (1.18; 1.50)
| | Parity 4 | 1.44 (1.27; 1.64)
| | Parity 5+ | 1.56 (1.38; 1.78)
| Frequent leaking urine | Parity 0 | 1 (1)
| | Parity 1 | 1.22 (1.08; 1.36)
| | Parity 2 | 1.37 (1.25; 1.51)
| | Parity 3 | 1.47 (1.33; 1.61)
| | Parity 4 | 1.58 (1.43; 1.74)
| | Parity 5+ | 1.72 (1.55; 1.90)
| At least enough to wet underwear | Parity 0 | 1 (1)
| | Parity 1 | 1.3 (1.13; 1.48)
| | Parity 2 | 1.41 (1.26; 1.58)
| | Parity 3 | 1.54 (1.37; 1.72)
| | Parity 4 | 1.62 (1.44; 1.82)
| | Parity 5+ | 1.83 (1.62; 2.05)
Hvidman, 2003 ^96^ | UI | Vaginal childbirths >1 | 3.1 (1.7; 5.8)
| | OR per vaginal birth | 1.53 (1.23; 1.90)
Uustal Fornell, 2004 ^185^ | UI | Children 2 (vs. 1–2) | 1.8 (1.2; 3.0)
Melville, 2005 ^124^ | Any UI | Number of deliveries | 1.2 (1.1; 1.2)
Moghaddas, 2005 ^191^ | Any UI | Nulliparity (yes) | 0.72 (0.58; 0.90)
| | Nulliparity (yes) | 0.81 (0.61; 1.10)
| | Nulliparity (yes) | 0.6 (0.42; 0.87)
Rohr, 2005 ^133^ | Any UI | No. of deliveries 0 | 1
| | 1 or 2 | 1.07 (0.90; 1.28)
| | 3+ | 1.2 (1.00; 1.44)
| Stress | No. of deliveries 0 | 1
| | 1 or 2 | 1.13 (0.93; 1.37)
| | 3+ | 1.27 (1.04; 1.55)
| Urge | No. of deliveries 0 | 1
| | 1 or 2 | 1.02 (0.83; 1.25)
| | 3+ | 1.04 (0.84; 1.28)
Danforth, 2006 ^138^ | UI | 1 birth | 1.4 (1.3; 1.5)
| | 2 births | 1.6 (1.5; 1.7)
| | ≥3 births | 1.6 (1.5; 1.7)
Waetjen, 2007 ^149^ | Prevalent incontinence | Nulliparous | Referent
| Any (at least monthly) | Parous | 1.43 (1.00; 2.03)
| Prevalent incontinence | Nulliparous | Referent
| Frequent (>weekly/daily) | Parous | 1.7 (1.05; 2.73)
| Incident incontinence | Nulliparous | Referent
| Any (at least monthly) | Parous | 1.31 (0.88; 1.96)
| Incident incontinence | Nulliparous | Referent
| Frequent (>weekly/daily) | Parous | 2.57 (0.58; 11.48)
| Prevalent stress | Nulliparous | Referent
| | Parous | 1.91 (1.31; 2.79)
| Prevalent mixed | Nulliparous | Referent
| | Parous | 2.16 (1.26; 3.71)
| Incident stress | Nulliparous | Referent
| | Parous | 1.44 (0.87; 2.40)
| Incident urge | Nulliparous | Referent
| | Parous | 0.92 (0.51; 1.68)
Foldspang, 1999 ^64^ | UI | Number of vaginal deliveries | 1.2 (1; 1.3)
Chen, 2003 ^95^ | Stress UI | Parities >2 | 2 (1.1; 3.8)
Rortveit, 2001 ^195^ | UI | 0 | 1
| | 1 | 1.6 (1.5; 1.8)
| | 2 | 1.8 (1.6; 1.9)
| | 3 | 2 (1.8; 2.2)
| | >4 | 2.3 (2.1; 2.5)
| Stress | 0 | 1
| | 1 | 1.9 (1.6; 2.2)
| | 2 | 2.3 (2.0; 2.6)
| | 3 | 2.4 (2.1; 2.7)
| | >4 | 2.3 (2.0; 2.7)
| Urge | 0 | 1
| | 1 | 1.2 (0.9; 1.6)
| | 2 | 1 (0.8; 1.3)
| | 3 | 1.1 (0.9; 1.5)
| | >4 | 1.5 (1.2; 1.9)
| Mixed | 0 | 1
| | 1 | 1.5 (1.2; 1.8)
| | 2 | 1.7 (1.4; 1.9)
| | 3 | 2.1 (1.8; 2.5)
| | >4 | 2.8 (2.4; 3.3)
| UI | 20–34 years 0 | 1
| | 20–34 years 1 | 2.4 (1.9; 2.9)
| | 20–34 years ≥2 | 2.8 (2.3; 3.3)
| | 35–64 years 0 | 1
| | 35–64 years 1 | 1.8 (1.5; 2.2)
| | 35–64 years ≥2 | 2 (1.6; 2.3)
| | >65 years 0 | 1
| | >65 years 1 | 0.8 (0.7; 1.1)
| | >65 years ≥2 | 1.1 (0.9; 1.3)
Fritel, 2005 ^135^ | Severe stress UI | 0 | 0.5 (0.3; 0.8)
| | 1 | 1
| | 2 | 1.2 (1.0; 1.6)
| | 3+ | 1.2 (0.8; 1.7)
Altman, 2006 ^196^ | Stress | 0 (baseline)
| | 1 | 2.4 (1.2; 4.3)
| | 2 | 1.7 (0.8; 1.9)
| | 3–4 | 1.9 (0.8; 3.1)
| Urge | 0 (baseline) | 1
| | 1 | 2.5 (0.4; 6.2)
| | 2 | 3.1 (0.5; 9.7)
| | 3–4 | 2.2 (0.7; 9.2)
Burgio, 1996 ^194^ | UI | Number of births | 1.218 (0.970, 1.529)
Wilson, 1996 ^193^ | UI | 3 months after delivery, parity 2 | 1.3 (1; 1.8)
| | 3 months after delivery, parity 3 | 1.4 (1; 2)
| | 3 months after delivery, parity 4 | 1.1 (0.6; 2)
| | 3 months after delivery, parity 5+ | 2.2 (1; 4.9)
| | 3 months after delivery, parity 2, continent before pregnancy | 1.5 (1; 2.4)
| | 3 months after delivery, parity 3, continent before pregnancy | 1 (0.6; 1.9)
| | 3 months after delivery, parity 4, continent before pregnancy | 1 (0.4; 2.9)
| | 3 months after delivery, parity 5+, continent before pregnancy | 0.9 (0.1; 8.2)

Figure 10. Odds ratios of UI in females with different numbers of births

Figure 11. Odds ratios of stress UI in females with different numbers of births

The role of parity is complex and changes as a woman ages. One study reported that age modified the association between parity and UI with a significant association in young and middle aged women and attenuation of the association in older females. ^195^ Particularly in studies of perimenopausal and postmenopausal an association has not been found between parity and UI or with UI type, ^118,^ ^128^ suggesting that aging tends to diminish this effect. In a study involving separate multivariate analyses in three age cohorts (ages 18–23, 45–50, and 70–75 years), the effect of increasing parity declined with age. ^68^ In other studies involving both cross-sectional and longitudinal analyses, the role of parity changes after 1 year. Odds ratios associated with parity are higher in women <60 years than in women ≥60 years. ^105^ Certain risk factors, such as vaginal delivery, are strong predictors of UI in younger women, but with changes associated with aging and menopause, this effect seems to disappear. In premenopausal women, the number of vaginal childbirths was strongly associated with UI. ^96^ In other studies, the relative risk of having stress UI 10 years after childbirth was not associated with the number of vaginal deliveries. ^196^

#### Obstetric and fetal factors

##### UI during and following pregnancy

Evidence suggests that UI developing during pregnancy is a risk factor for UI in the immediate postpartum period ^197^ and in subsequent years ^64,^ ^96^ raising the odds of UI by two to 11 times ^96,^ ^198^ (Appendix Table F18). One study found that the odds of developing UI, stress, urge, and mixed UI were 2.2, 3.4, and 3.2 times higher, respectively, for women who had UI during pregnancy than women who did not. ^64^

Women who experienced postpartum UI had four to five times higher odds of developing UI, ^64,^ ^119^ with four times higher odds for developing stress UI, and 2.6 and 3.2 odds for developing urge and mixed incontinence, respectively. ^64^

##### Mode of Delivery

The majority of the studies report that spontaneous vaginal deliveries are more likely to be associated with UI, ^7,^ ^197,^ ^199^ stress UI and severe stress UI, ^135^ and subsequent stress UI surgery ^631^ compared to Cesarean delivery (labored and unlabored). Cesarean section was associated with lower odds of UI in seven studies, ^119,^ ^197,^ ^199^ – ^203^ by 80 percent ^201^ to 41 percent ^200^ and did not show a significant association in five studies ^135,^ ^141,^ ^196,^ ^204,^ ^205^ (Table 19). Two studies reported higher odds of UI when women after Cesarean section were compared with nulliparous females (Figure 12). ^7,^ ^206^ Vaginal delivery compared to Cesarean increased the risk of total UI with little evidence of association with stress and urge UI. Adjusted odds of UI was higher after forceps delivery by 150 percent ^199^ to 187 percent ^198^ compared to vaginal delivery (Figure 13), by 310 percent to 430 percent ^199^ compared to Cesarean section, and by 430 percent compared to nulliparous women. ^206^ Vacuum delivery was associated with random changes in UI in the majority of the studies (Table 19). One study found that previous pregnancy was a risk factor for severe stress UI in women who reached the age of 50, although the mode of delivery had less effect. ^135^ Breech delivery was not associated with an increased risk of UI or any UI type. ^98^

Table 19 Odds ratio of UI according to delivery

Author | Urinary Incontinence | Delivery | Odds Ratio (95% CI)
Cesarean
Rortveit, 2003 ^206^ | Any UI | Cesarean vs. nulliparous | 1.5 (1.2; 1.9)
| Moderate/severe UI | Cesarean vs. nulliparous | 1.4 (1.0; 2.1)
MacLennan, 2000 ^7^ | Mixed | Cesarean only vs. nulliparous | 2.5 (1.5; 4.3)
| | Both vaginal and Cesarean vs. nulliparous | 4.7 (2.3; 9.3)
Fritel, 2005 ^135^ | Severe stress UI | Caesarean vs. vaginal | 0.8 (0.5; 1.3)
Chaliha, 1999 ^205^ | Stress | Cesarean vs. vaginal | 1 (0.8; 1.2)
| Urge | Cesarean vs. vaginal | 0.5 (0.2; 1.1)
Hojberg, 1999 ^204^ | UI | Caesarean at 1 pregnancy vs. nulliparous | 1.3 (0.4; 4.3)
Farrel, 2001 ^199^ | UI | 6 weeks after labored Cesarean vs. elective Cesarean | 2.3 (0.3; 17.6)
| | 6 weeks after Cesarean in second stage vs. elective Cesarean | 1.2 (0.1; 12.2)
| | 6 weeks after Cesarean in labor vs. vaginal | 0.4 (0.2; 0.8)
| | Labored Cesarean vs. elective Cesarean | 2.5 (0.3; 18.5)
| | Cesarean in second stage vs. elective Cesarean | 0.6 (0.04; 9.1)
| | Cesarean in labor vs. vaginal | 0.6 (0.3; 1.0)
Thompson, 2002 ^200^ | UI | 8 weeks after Cesarean vs. vaginal | 0.25 (0.14; 0.44)
| | 16 weeks after Cesarean vs. vaginal | 0.59 (0.35; 0.99)
| | 24 weeks after Cesarean vs. vaginal | 0.55 (0.31; 0.98)
Hvidman, 2003 ^201^ | UI | Cesarean vs. vaginal | 0.2 (0.06; 0.9)
Schytt, 2004 ^119^ | UI | Cesarean vs. vaginal | 0.5 (0.3; 0.9)
Casey, 2005 ^202^ | UI | Cesarean vs. vaginal | 0.5 (0.3; 0.8)
Glazener, 2006 ^197^ | UI | Caesarean vs. vaginal | 0.28 (0.19; 0.41)
Lukacz, 2006 ^141^ | UI | Cesarean vs. nulliparous | 1.3 (0.82; 1.9)
Burgio, 2007 ^203^ | UI | Cesarean vs. vaginal | 0.5 (0.3; 0.9)
Altman, 2006 ^196^ | Stress | Episiotomy vs. noninstrumental | 0.9 (0.3; 2.6)
| Urge | Episiotomy vs. noninstrumental | 1.7 (0.5; 4.1)
Forceps
Rortveit, 2003 ^206^ | Any UI | Forceps vs. no forceps | 0.9 (0.7; 1.1)
| Mixed | Forceps vs. no forceps | 1 (0.7; 1.3)
| Moderate severe UI | Forceps vs. no forceps | 0.9 (0.7; 1.2)
| Stress UI | Forceps vs. no forceps | 0.9 (0.7; 1.1)
| Urge | Forceps vs. no forceps | 0.8 (0.4; 1.5)
MacLennan, 2000 ^7^ | Mixed | At least one forceps vs. nulliparous | 4.3 (2.8; 6.6)
Fritel, 2005 ^135^ | Severe stress UI | Forceps vs. vaginal | 0.8 (0.6; 1.1)
Farrel, 2001 ^199^ | UI | 6 weeks after forceps | 1.3 (0.6; 2.5)
| | 6 weeks after forceps vs. vaginal | 1.5 (1.1; 2.2)
| | 6 weeks after forceps vs. Cesarean | 4.3 (2.2; 8.2)
| | 6 months after forceps vs. vaginal | 1.5 (1.0; 2.3)
| | Forceps vs. Cesarean | 3.1 (1.7; 5.9)
Burgio, 2003 ^198^ | UI | Forceps vs. vaginal | 1.87 (1.1; 3.22)
Casey, 2005 ^202^ | UI | Forceps vs. vaginal | 1.5 (0.8; 2.6)
Glazener, 2006 ^197^ | UI | Forceps/breech vs. vaginal | 1.18 (0.92; 1.51)
Vacuum Delivery
Rortveit, 2003 ^206^ | Mixed | Vacuum vs. no vacuum | 0.8 (0.5; 1.1)
| Moderate severe UI | Vacuum vs. no vacuum | 0.8 (0.6; 1.1)
| Stress UI | Vacuum vs. no vacuum | 0.8 (0.6; 1.0)
| Any UI | Vacuum vs. no vacuum | 0.8 (0.7; 1.0)
| Urge | Vacuum vs. no vacuum | 1.2 (0.7; 2.2)
Altman, 2006 ^196^ | Stress | Vacuum extraction vs. noninstrumental | 1.8 (0.3; 2.7)
| Urge | Vacuum extraction vs. noninstrumental | 1.5 (0.4; 5.5)
Hvidman, 2003 ^201^ | UI | Vacuum extraction or forceps vs. vaginal | 0.2 (0.03; 0.8)
Glazener, 2006 ^197^ | UI | Vacuum vs. vaginal | 1.16 (0.83; 1.63)
Schytt, 2004 ^119^ | UI | Vacuum extraction or forceps vs. vaginal | 1.1 (0.7; 1.8)
Vaginal Delivery
MacLennan, 2000 ^7^ | Mixed | Vaginal only vs. nulliparous | 3.4 (2.4; 4.9)
Rortveit, 2003 ^206^ | Moderate/severe UI | Vaginal vs. nulliparous | 2.6 (2.1; 3.1)
| Any UI | Vaginal vs. nulliparous | 2.3 (2.0; 2.6)
Chen, 2003 ^95^ | Stress UI | Vaginal | 1.3 (0.9; 2.1)
Hojberg, 1999 ^204^ | UI | First, vaginal vs. nulliparous | 5.7 (3.9; 8.3)
| | Parity >3; only vaginal vs. nulliparous | 4.8 (3.0; 7.9)
| | Parity 3; only vaginal vs. nulliparous | 7.7 (3.9; 15.3)
Farrel, 2001 ^199^ | UI | 6 weeks after vaginal vs. Cesarean | 2.8 (1.5; 5.3)
| | 6 months after vaginal vs. Cesarean | 2.1 (1.1; 3.7)
Burgio, 2003 ^198^ | UI | 12 months after vaginal vs. baseline | 2.36 (1.36; 4.1)
Lukacz, 2006 ^141^ | UI | Vaginal parous vs. nulliparous | 2.3 (1.7; 3.0)
| | Vaginal parous vs. Cesarean | 1.8 (1.3; 2.6)
| | Vaginal parous vs. unlabored Cesarean | 3.9 (1.5; 9.2)
| | Vaginal parous vs. labored Cesarean | 1.6 (1.0; 2.6)
Borcello-France, 2006 ^231^ | UI | Vaginal vs. Cesarean | 1.3 (0.8; 2.3)

Bold - significant association at 95% confidence level

Figure 12. Odds ratio of UI after vaginal delivery compared to Cesarean section

Figure 13. Odds ratio of UI after forceps delivery compared to vaginal or no forceps

Few prospective studies reported protective effects of Cesarean section on UI compared to vaginal delivery. ^119,^ ^197,^ ^202,^ ^205^

##### Oxytocin

The prior use of oxytocin significantly increased the odds of UI by 1.9 times in women ≥60 years. ^59^

##### Epidural analgesia

Evidence does not support that epidural analgesia increases the risk of incontinence. ^98^

##### Duration of labor

Several studies have examined labor time and the duration of specific stages of labor. One study found that labor time, duration of second, passive, and active stages, as well as the duration that the fetal head was deeply engaged was not associated with UI. ^199^ Another study found that labor beyond 24 hours was not associated with UI. ^59^ In contrast, a study found that functional delivery disorders increased the odds of having moderate/severe UI. ^98^

##### Episiotomy, lacerations, and perineal suturing

Episiotomy has not been associated with UI, either having had one or several episiotomies. ^59,^ ^64,^ ^196^ Perineal rupture and perineal suturing were not significantly associated with UI. ^59,^ ^64,^ ^196^

##### Gestational age

Relatively few studies have examined gestational age as a risk factor for UI. Studies available do not support an independent association with UI. ^59,^ ^98,^ ^197^

##### Fetal weight and head circumference

There is inconsistent data on the effect of fetal weight on UI. Two studies found that heavier babies increased the risk of UI. ^98,^ ^197^ In one study, heavier babies (birth weight in the top quartile or ≥4,000 grams increased the odds of becoming incontinent by 10–56 percent, ^98^ and in another a heavier fetal weight increased the odds of developing stress UI but not urge or mixed UI. ^98^ However, most studies do not report a significant association between fetal weight and UI. ^196,^ ^199^ Relatively few studies have examined fetal head circumference as a risk factor. Data from three studies indicate that it is not an independent risk factor for UI, ^98,^ ^199^ although one study found it to significantly increase the odds of urge UI by 80 percent. ^98^

##### Lactation

Breast feeding as a risk factor for subsequent UI has been examined in a few studies with conflicting findings. ^96,^ ^198^ Although lactation was associated in bivariate analysis with UI, in multivariate analyses, it was not independently associated with UI. ^96^ In another study, length of breast-feeding slightly increased the odds of UI by 17 percent. ^198^

#### Menstrual cycle and menopause

Because of the presence of estrogen and progesterone receptors in the lower urinary tract, female UI is assumed to be associated with a woman's hormonal status and the fluctuations in it (Appendix Table. F19). One study 2,158 premenopausal women in Denmark examining the role of hormonal variation found that self-reported UI the day before completing a survey questionnaire was strongly associated with a recent decrease in bleeding duration (OR 2.2, 95 percent CI 1.3; 3.6). ^96^

Because of the increased prevalence of UI in the perimenopausal years, menopause has been assumed to be a key risk factor in UI. One study found that perimenopausal status was independently associated with UI, increasing the odds by 127 percent (OR 1.3, 95 percent CI 1.1; 1.5). ^93^ The large Women's Health in the Lund Area study found an increase in adjusted odds of UI by 144 percent among premenopausal women (OR 1.4, 95 percent CI 1.1; 1.8) and by 1.5 percent in depressed premenopausal women (OR 1.5, 95 percent CI 1.1; 2.0). ^191^ Studies examining menopause assessed by self report have not found it to be an independent risk factor for stress UI. ^70,^ ^95^ Although menopause was not found to be significantly associated with UI, the number of years past menopause did increase the odds of UI by 15 percent, suggesting the aging process may have a greater role in the development of UI than hormonal status. ^90^

#### Gynecological or abdominal surgery

There is mixed evidence related to prior gynecological surgery as a risk factor (Appendix Table F20). Five ^55,^ ^83,^ ^108,^ ^124,^ ^138^ studies of eight ^55,^ ^62,^ ^72,^ ^83,^ ^108,^ ^124,^ ^138,^ ^144,^ ^191^ that examined this association reported significantly higher adjusted rates of total UI among women after hysterectomy. The increase was 160 percent (OR 1.6, 95 percent CI 1.1; 2.1) for UI in the past month, ^108^ 130 percent for at least monthly UI (OR 1.3, 95 percent CI 1.1; 1.6), ^124^ 140 percent for daily UI (OR 1.4, 95 percent CI 1.1, 1.6), ^55^ and 160 percent for severe UI (OR 1.6; 95 percent 1.5; 1.7). ^138^ In contrast, rates of stress UI were either the same after hysterectomy in four studies ^87,^ ^108,^ ^118,^ ^135^ or were less in the Women's Health Australia study (OR 0.8, 95percent CI 0.7; 0.9). ^68^ Women after hysterectomy also had the same prevalence of urge UI in three studies. ^70,^ ^74,^ ^108^ Only one European cross-sectional study reported higher adjusted odds of bothersome urge UI among women after hysterectomy (OR 2.6, 95 percent CI 1.4; 4.4). ^87^ Depressed women after hysterectomy had UI 1.3 times more often (OR 1.3, 95 percent CI 1.0;1.7). ^191^ Diabetics after hysterectomy also had increased adjusted rates of weekly UI (OR 2.3, 95 percent CI 1.0; 5.2). ^140^

Evidence on the relationship between UI and other gynecological conditions and procedures is conflicting (Appendix Table F21). Women with previous gynecological surgery had stress UI twice as often (OR 2, 95 percent CI 1.1; 3.7). ^95^ Women with prolapse (OR 4.11, 95 percent CI 2.15; 7.86) ^92^ and after prolapse surgery had increased odds of UI. ^62,^ ^68^ In another study, pelvic organ prolapse surgery was not significantly associated with UI. ^135^ Women who had both a hysterectomy and prolapse repair were 1.8 to 2.3 times more likely to have UI compared to women without these surgeries. ^68^

Other surgeries on the uterus, excluding hysterectomies, led to conflicting findings, depending on the measurement of UI, when UI was confirmed by objective measures, they did raise the odds of having UI by 2.2 times, but when self report was used as the UI measure, there was no association. ^62^ In another study of premenopausal women, having had abdominal or gynecological surgery was associated with a 170 percent higher risk when compared to women without this surgery; ^96^ and in another study involving both premenopausal and postmenopausal women, prior gynecological surgery doubled the odds of having UI. ^95^

#### Pelvic floor muscle contraction strength

Two studies examined the role of pelvic floor muscle contraction or exercises on either the prevalence or incidence of UI. In one cross-sectional study involving 507 women who completed a clinical evaluation, poor ability to contract pelvic floor muscles was strongly associated with UI (adjusted odds ratio of 3.5 for objectively confirmed according to the ICS definition UI and 4.5 for self-reported UI) depending on the definition of UI. ^62^ In a study of primiparous women, inability to interrupt urine flow doubled the odds of being incontinent. ^636^

#### Other factors

One clinical study found that abnormal findings on a gynecological examination were significantly associated with having UI in women ages 50–74. ^62^ Vaginal symptoms (dryness, discharge, itching, dyspareunia) in postmenopausal women are significantly associated with any UI and severe UI. ^144^ In this same study, atrophic vaginitis was significantly associated with any UI but not severe UI. Vaginal colonization with E. coli was not independently associated with any or severe UI. ^144^

In a study of 665 primiparous women, perceived discomfort in the lower abdomen increased the odds of UI by 3.6 times. ^636^ One large survey of middle-aged American women found that fibroids were associated with prevalent UI but not incident UI. ^149^

### Urological Factors

#### Childhood voiding dysfunction

There is limited evidence available on the role of childhood voiding dysfunctions as a risk factor for UI in adulthood. Evidence available suggests that childhood nocturnal enuresis is associated with the development of UI in adulthood, particularly urge UI. In one study, the odds of having UI were increased by 2.4 times among premenopausal women. ^96^ In two other studies, childhood nocturnal enuresis increased the odds of urge UI by 2.7 times. ^70,^ ^637^ but was not associated with stress UI. ^70^ It was also associated with increasing the risk of severe UI almost 3-fold.(Kuh, 1999, #1578). Childhood daytime incontinence has also shown to be associated with adult urge UI (OR 2.6, 95 percent CI 1.1; 5.9). ^637^

#### Lower urinary tract symptoms

Few epidemiological studies have examined the association of lower urinary tract symptoms (urgency, frequency, nocturia, dysuria, difficulty with bladder emptying) as independent risk factors for either prevalent or incident UI. Findings are inconsistent across studies (Appendix Table F22). Urinary frequency was independently associated with UI in women ≥60 years, ^42^ whereas it was not associated with UI risk in women ages 20–84 years. ^139^ Urgency increased the odds of UI by 9.3 times in women ages 60–84 years, but was not found to be associated in those ≥85 years. ^42^ However, in another study with women ages 20–84 years, urgency did not predict UI risk. ^139^ Nocturia increased the odds of UI in women ≥85 years but not in those ages 60–84. ^42^ Stinging or burning urine was significantly associated with UI in three age cohorts (ages 18–23, 45–50, and 70–75 years). ^68^

In a study of postpartum women, frequency of urination increased the odds of having UI one year after delivery. ^198^

#### Urinary tract infections

There is inconsistent data on the role of urinary tract infections as a risk factor for UI (Appendix Table 23). Women with urinary tract infections had higher rates of UI in 11 studies ^66,^ ^72,^ ^74,^ ^90,^ ^92,^ ^97,^ ^108,^ ^116,^ ^121,^ ^127,^ ^144^ of 15 ^66,^ ^70,^ ^72,^ ^74,^ ^90,^ ^92,^ ^96,^ ^97,^ ^106,^ ^108,^ ^116,^ ^121,^ ^127,^ ^144,^ ^187^ that examined the association. Women with recurrent urinary tract infection had the highest increase in UI by 230 percent for weekly UI (OR 2.3, 95 percent CI 1.3; 3.9) ^127^ and for monthly UI (OR 2.3, 95 percent CI 1.6; 3.1), ^108^ 220 percent for UI in the past year (OR 2.2, 95 percent CI 1.4; 3.4), ^72^ and by 470 percent for ever having UI (OR 4.7, 95 percent CI 4.7; 8.9). ^116^

Several studies reported that menopausal status can influence the association between urinary tract infections and UI. One study in premenopausal women, ^96^ one study in postmenopausal women, ^106^ and one study that included both premenopausal and postmenopausal women did not find a significant increase in odds of UI among women with urinary tract infection. ^139^ In contrast, one survey in postmenopausal women found that the lifetime number of urinary tract infections (six or more) increased the risk of UI by 1.9 times for any UI and 2.0 times for severe UI. ^144^ Two studies found urinary tract infection increased the odds of UI by 4.8 times in women who were perimenopausal and by 3.4 in women who were menopausal. ^90,^ ^152^

Urinary tract infections have been associated with UI type; in one survey two or more urinary tract infections in the past year doubled the odds of having urge UI. ^66^ In another study, cystitis was significantly associated with stress UI at baseline and 1 year later, increasing the odds of stress UI by 50 to 90 percent. ^132^

#### Postvoid residual bladder volume

One study found that postvoid residual bladder volume was not associated with UI in postmenopausal women. ^128^

#### Bladder or urinary surgery

Several studies have examined whether prior bladder or urinary surgery is a risk factor for UI. Some studies have not found significant associations, ^144^ whereas another study found that UI surgery doubled the odds of having UI in perimenopausal women. ^135^

### Medical Conditions

#### Arthritis and musculoskeletal disorders

Evidence from three studies, ^7,^ ^86,^ ^118^ suggested that women with arthritis had higher rates of UI (Figure 14). Two studies found that arthritis was associated with increased odds of UI by 80–88 percent. ^7,^ ^86^ Arthritis was also an independent risk factor for UI type. In a study involving women ages 70–79 years, arthritis was significantly associated with both urge and stress UI. ^118^

Figure 14. Association between arthritis and UI in women

Joint pain was significantly associated with stress UI in a 1-year followup study, increasing the odds of UI by 40 percent. ^132^ A history of hip fracture increased the odds of UI by 38 percent. ^81^ Osteoporosis was associated with UI in one study, ^7^ but the association can be confound by age.

#### Diabetes

There is growing evidence to suggest that diabetes mellitus increases the odds of having UI (Appendix Table F24). Two studies ^134,^ ^149^ of three ^134,^ ^149,^ ^186^ reported that women with diabetes develop UI more often. Incidence of weekly UI was higher by 147 percent (OR 1.5; 95 percent CI 1.2; 1.9) in women with duration of diabetes more than 10 years. ^134^ The same Nurses' Health Study cohort showed that incidence of severe UI was increased by 175 percent (OR 1.8, 95 percent CI 1.3, 2.3) and very severe by 126 percent (OR 2.6; 95 percent CI 1.4; 5.0). ^134^ The Study of Women's Health Across the Nation found 302 percent increase in developing monthly UI in women with diabetes independent on other risk factors (OR 3.0, 95 percent CI 1.1; 8.1). ^149^

Prevalence of stress UI was greater in women with diabetes in three studies ^95,^ ^133,^ ^149^ of six ^66,^ ^95,^ ^108,^ ^133,^ ^135,^ ^149^ that examined the association (Figure 15). Pooled odds ratio of prevalent stress UI was not significant (OR 1.4, 95 percent 0.9; 2.1). The result of meta-analysis was sensitive to one study, The Heart & Estrogen/Progestin Replacement Study Research Group, randomized trial of 2,763 women taking combination hormone therapy to prevent coronary heart disease, that did not find a significant association between diabetes and stress UI. ^66^ However, the majority of the studies reported a significant increase in adjusted odds of total UI among women with diabetes (Figure 16) ^55,^ ^66,^ ^72,^ ^86,^ ^93,^ ^97,^ ^108,^ ^116,^ ^124,^ ^127,^ ^128,^ ^133,^ ^134,^ ^138,^ ^149,^ ^186^ Pooled analysis of 16 studies resulted in an odds ratio of 1.4 (95 percent CI 1.2; 1.5) of having prevalent UI in women with diabetes. Four of five studies found a significant increase in adjusted odds of urge UI among women with diabetes (Figure 17). ^66,^ ^108,^ ^118,^ ^133,^ ^149^ Pooled analysis of five studies estimated that diabetic women had urge UI 1.7 times more frequently than nondiabetics (95 percent CI 1.2; 2.2).

Figure 15. Association between prevalent stress UI and diabetes in females

Figure 16. Association between prevalent UI and diabetes in women

Figure 17. Association between prevalent urge UI and diabetes in women

Diabetic complications such as macroalbuminuria, retinopathy, and/or peripheral neuropathy significantly increased the odds of having UI in two studies. ^128,^ ^140^ Diabetic neuropathy was associated with an adjusted odds ratio of 2.4 and macroalbuminuria increasing the odds by 3.8. ^140^ However, in another study, a BMI adjustment decreased the strength of these associations. ^128^ This same study also found that neither diabetes treatment (diet, pill, or insulin) nor duration of treatment was associated with UI after adjustment for BMI. Blood glucose control as measured by HbA_1c_ was also not associated with UI. ^128^ Women who have insulin-dependent diabetes were found to have a 3.5 times higher risk of urge UI when compared to women without diabetes. ^128^

#### Stroke

One prospective cohort, the Canadian Study of Health and Aging, found that elderly community dwelling women had higher risk of developing UI after stroke (OR 1.6, 95 percent CI 1.1; 2.2). ^207^ Prevalence of UI was significantly higher among women after stroke in five ^55,^ ^86,^ ^97,^ ^133,^ ^186^ of six ^55,^ ^67,^ ^86,^ ^97,^ ^133,^ ^186^ studies that examined this association (Figure 18) Pooled analysis of six studies estimated an increase by 167 percent of UI in women with history of stroke (OR 1.7 95 percent CI 1.4; 2.1). Severe UI was more prevalent in women with history of stroke in one study (OR 1.9, 95 percent CI 1.4; 2.8). ^67^ Paraplegia was also associated with UI (OR 1.6, 95 percent CI 1.1; 2.6). ^133^

Figure 18. Association between stroke and prevalent UI in women

#### Neurological disorders

There is conflicting evidence on neurological diseases and prevalent UI (Appendix Table F25). Women with any neurological diseases had greater rates of ever having UI (OR 3.8, 95 percent CI 1.7; 8.6). ^116^ Parkinson's disease was associated with increased odds of having UI in one study (OR 2.3, 95 percent CI 1.1; 4.5) ^81^ while two other studies ^97,^ ^133^ did not find a significant association.

#### Pulmonary disorders

Asthma and chronic obstructive pulmonary disease (COPD) have been studied as potential risk factors for UI in several studies with conflicting findings (Appendix Table F26). Although most studies find COPD to predict UI risk, ^81,^ ^124,^ ^133^ in a large study involving 29,520 women, ^86^ COPD was not associated with UI. In a smaller survey involving 1,531 women ≥65 years, COPD increased the odds of UI by 53 percent. ^81^ In other studies, COPD was associated with the type of UI. In women ages 55–75 years, the odds of having stress UI were increased five-fold, although it was not associated with urge UI risk. ^118^ Asthma was not associated with UI risk in one study, ^86^ whereas in another study it increased the odds of stress UI by 50 percent at baseline but was not significantly associated 1 year later. ^132^ Several studies indicated that frequent or prolonged coughing increases the odds of UI by 33 to 60 percent ^114,^ ^638^

#### Comorbidity and poor health

Some studies have examined the role of comorbidity in relation to UI (Appendix Table F26). Elderly community dwelling women with kidney problems (OR 1.7, 95 percent CI 1.2; 2.3) and foot diseases (OR1.4, 95 percent CI 1.0; 1.8) were at risk of developing UI. ^186^ Women with two or more comorbid diseases had higher adjusted rates of UI (OR 5.9, 95 percent CI 3.7; 9.6). ^92^ Increased comorbidity index was associated with higher adjusted odds of UI in three studies. ^121,^ ^124,^ ^189^

In studies involving community dwelling females, poor self-rated health increased the odds of having daily UI by 60 percent ^55^ and was weakly associated with stress UI. ^118^ In another study, poor health was not associated with stress or urge UI in post-menopausal women; however, it did increase the odds of having mixed UI by 143 percent (OR 1.4, 95 percent CI 1.1; 1.8). ^66^ In a large survey of women ages 40–55 years, poor health was associated with increased odds of urge UI but not mixed or stress UI. ^149^ Women with poor or fair health experienced UI 2.6 ^187^ to 2.9 ^84^ times more often.

#### Cardiovascular disorders

There is limited evidence on the role of cardiovascular disorders such as heart problems and hypertension on UI (Appendix Table F26). Hypertension was strongly associated with UI in two studies, ^83,^ ^127^ whereas two studies did not find a significant association with any UI ^639^ or with stress UI. ^95^ In large surveys, heart problems, ^639^ including congestive heart failure, ^55,^ ^97^ were not associated with UI.

#### Gastrointestinal diseases and procedures

##### Constipation

A limited number of studies have explored the role of constipation as a UI risk factor (Appendix Table F27). ^68,^ ^144,^ ^152^ Three studies ^68,^ ^121,^ ^144^ reported a significant increase in adjusted odds of UI in women with constipation among six studies that examined this association. ^68,^ ^74,^ ^97,^ ^121,^ ^144^ One study found that constipation increased the odds of having severe UI by 50 percent, whereas it was weakly associated with having any UI. ^144^ In another study involving different multivariate analyses in three age cohorts (ages 18–23, 45–50, and 70–75 years), constipation nearly tripled the odds of having UI. ^68^ However, two studies did not find a significant association between constipation and UI; one study in homecare patients ^97^ and the other with women ages 45 years and over. ^143^ Bowel straining significantly increased the odds of stress UI at baseline by 150 percent; however, the effect was not present 1 year later. ^132^ Constipation was not associated with urge UI. ^74^ Constipation 4–6 weeks after childbirth was independently associated with UI at 1-year postpartum in all women (primiparae and multiparae women combined), and in primiparae alone but not in multiparae women. ^119^ Women with bowel symptoms had higher adjusted rates of UI in one study ^68^ with random findings in another. ^185^ One study ^96^ of seven reported a significant increase in prevalence of UI after abdominal surgery. ^72,^ ^96,^ ^108,^ ^135,^ ^144,^ ^185^

#### Other surgical procedures

One study found that varicose veins and hemorrhoids were independently associated with UI at 1-year post-partum in primiparous women by 50 percent. ^640^ Previous surgery for UI was associated with increased odds of weekly UI (OR 1.4, 95 percent CI 1.2; 1.8) ^83^ and stress UI (OR 1.3, 95 percent CI 1.3; 4). ^135^ In one study, urological surgeries were not associated with prevalent UI in women. ^72^

### Medications

Relatively few studies have investigated the independent effect of medications on prevalent or incident UI (Appendix Table F28).

#### Incident UI

Only one study reported incident UI in women with diabetes treated with pharmacological agents and found that insulin administration but not oral medications were association with a 350 percent increase in developing of UI (OR 3.5, 95 percent CI 1.6; 7.9). ^123^

#### Diuretics

The evidence on the role of diuretics on UI risk is conflicting. Earlier studies that examined bivariate associations indicated that diuretics were associated with UI in older adults. ^641^ However, large studies involving multivariate analyses did not find that diuretics including nonthiazide diuretics increased the odds of having UI. ^55,^ ^86^ Diuretics is a strong predictor of UI type, particularly urge UI. ^133^ One study found that diuretics significantly increased the odds for stress and urge UI in women ages 40–60 years by two to four times. ^78^

#### Estrogen

Several epidemiological studies have examined estrogen therapy as a risk factor for UI (Appendix Table F29). ^55,^ ^59,^ ^105,^ ^118,^ ^144,^ ^191^ The risk of UI is elevated among women taking postmenopausal hormones (oral and transdermal estrogen with and without progestin) as compared to those who have never taken them. ^153^ Women taking transdermal estrogen with and without progestin (RR 1.7, 95 percent CI 1.4; 2.06 and RR 1.5, 95 percent CI 1.2; 1.8, respectively) had a slightly higher risk of UI than those who took the oral forms (RR 1.5, 95 percent CI 1.4; 1.6 and RR 1.3, 95 percent CI 1.2; 1.4). This same study also found there was little risk after cessation of hormones and a decreasing risk of incontinence with increasing time since last hormone use. ^105^ Ten years after stopping hormone use, the risk was identical in women who had and had not taken hormone therapy. Two studies found that oral hormone replacement therapy increased the odds of having UI by 1.9 times. ^55,^ ^59^ Vaginal estrogen cream use was significantly associated with any UI in women ages 55–75 years, although this same association was not found with severe UI. ^144^ Systemic hormone replacement therapy is strongly associated with urge and stress UI. In a study of 1,584 women ages 70–79 years, current oral estrogen use increased the odds of urge UI by 70 percent and stress UI by 98 percent, respectively. ^118^ Hormone use for menstrual disorders was also an independent risk factor for UI. ^96^ Former use of oral contraceptives increases the odds of UI by 18–20 percent, although current use was not associated. ^138^

#### Psychotropic medications

A few studies have examined whether antidepressants in general or specific types of antidepressants are a risk factor for UI. In a large survey, antidepressant use was associated with increased odds of having UI by 75 percent. ^86^ In a study involving 6,642 women, the use of selective serotonin reuptake inhibitors (SSRIs) or serotonin norephinephrine reuptake inhibitors (SNRIs) was not associated with UI in multivariate models that included all women, depressed women only, and nondepressed women who reported depressive symptoms. ^191^ However, in a subanalysis of depressed women on SSRI/SNRIs, there was a significant association between drug use and UI. ^191^ Tranquilizers have been shown to increase the risk of UI by 65 percent. ^86^ The contribution of psychotropic medications, independent from baseline disease on UI, has not been examined in prospective observational studies. The results from RCTs showed that serotonin-noradrenaline reuptake inhibitor, duloxetine improved stress UI, ^642^ suggesting that depression rather than the antidepressant could be considered as a risk factor for UI.

#### Other medications

In a large survey of 29,520 women, pain, narcotics, asthma, hypertensive, and heart medications were not associated with an increased risk of UI. ^86^ In this same survey, antibiotics were significantly associated with UI, increasing the odds by 64 percent, laxatives by 67 percent, and hypnotics by 52 percent. However, another study did not find an association between sleeping medications and UI risk. ^106^ Polypharmacy (e.g., three drugs or more) was not associated with UI risk in women ages 70 years and over. ^106^

#### Summary

Limited evidence, Level IIA from prospective cohort studies suggested that increased BMI, diabetes, comorbidities, cognitive decline, and hormone therapy were associated with developing UI in community dwelling females. Prevalence of UI was higher in aging and depressed women, after stroke, vaginal trauma, and in women with physical dependency. The strength of the association depends on definitions of UI by time, type, and severity. Differences in assessment of associated factors may also contribute to the effects on UI. Hormone status of women modified the effects of other associated factors. Comparisons across the studies were difficult to make due to methodological heterogeneity in adjustment and statistical models.

## Risk Factors for UI in Community Dwelling Men

The prevalence of UI in elderly males with different risk factors was examined in one population based survey (Appendix Table F30). ^607^ Men with arthritis had the highest prevalence of mixed (51 percent), urge (43 percent), and stress UI (46 percent) compared to other internal diseases. Mixed UI was reported in 29–39 percent of males with hearing and vision problems; 35 percent reported urge UI. Diabetics experienced stress UI more often than men with other diseases (36 percent). Urge UI was prevalent in men with pulmonary diseases (27 percent). The prevalence of UI was 36 percent in men who used diuretics, 38 percent in men treated for prostate problems, and 60 percent in those taking antispasmodic agents ^181^ After prostate surgery (47 percent) and bladder surgery (58 percent of men) had a higher prevalence of UI. ^181^ However, one European survey of 840 men reported lower compared to other studies prevalence of UI after transvesical prostatectomy for benign prostatic hyperplasia. ^643^

The prevalence of UI in men with prostate cancer varied from less than 1 percent ^173^ to 30 percent ^180^ and 44 percent ^181^ being lower than 10 percent in the majority of the studies ^167^ – ^174^ (Appendix Table F31). The rates of UI in men treated for prostate cancer varied substantially depending on the treatment use, time of followup, population characteristics, and definitions of UI (Appendix Table F32). The largest case series reported that 8 percent of men experienced UI after radical prostatectomy (Appendix Table F33). ^644^ A retrospective analysis of a national random sample of 12,079 Medicare beneficiaries showed that the incontinence rate after radical prostatectomy decreased from 20 percent in 1991 to 4 percent in 1995, being the highest in older patients. ^175^ One prospective population-based cohort, the Prostate Cancer Outcomes Study, found differences in the rates of occasional and frequent UI after radical prostatectomy. ^172^ The rates of UI after radiation therapy differed across the published case series. The largest (1,192 males followed for 52 months after external beam radiotherapy) reported 5 percent with Grade 1 UI using the modified Radiation Therapy Oncology Group/Subjective, Objective, Management, and Analytic scale (Grade I - Occasional [less frequent than weekly] use of incontinence pads). ^170^

Associations between UI and risk factors were reported in several studies (Table 20). ^72,^ ^74,^ ^81,^ ^83,^ ^84,^ ^86,^ ^92,^ ^97,^ ^170,^ ^174,^ ^175,^ ^180^ – ^182,^ ^644^ Age was an independent risk factor for UI in two studies. ^58,^ ^97^ One study reported crude significant association, ^81^ not confirmed in the largest retrospective cohort study of Medicare beneficiaries. ^175^ Limited evidence suggested that age was significantly associated with urge UI (OR 5.34, 95 percent CI 2.26; 12.62) among those older than 70 years compared to younger men, ^74^ with random association with stress UI. ^645^ Non-White men had the same rates of UI compared to Whites. ^175^ Marital status ^84^ and education in men ^72,^ ^83,^ ^92^ were not associated with lower odds of UI. Two studies showed that a sedentary lifestyle was associated with UI in males. ^83,^ ^92^

Table 20 Association between age, race, and behavioral risk factors with male UI

Author | Sample | Level of Risk Factors | Relative Measure of the Association (95% CI)
Age (total)
Maggi, 2001 ^81^ | 867 | Age >70 years | 2.49 (1.45; 4.28)
Landi, 2003 ^97^ | 2,178 | 75–84 vs. 65–74 | 0.97 (0.66; 1.44)
| 2,178 | >85 vs. 65–74 | 1.99 (1.39; 2.84)
Hu, 2003 ^175^ | 12,079 | Age 70–74 vs. 65–69 | 0.97 (0.84; 1.12)
| 12,079 | Age >74 vs. 65–69 | 0.99 (0.83; 1.17)
Nakanishi, 1997 ^58^ | 1,405 | Age >75 | 4.99 (2.63; 9.44)
Nelson, 2005 ^4^ | 2,559 | Age (per year) | 1.03 (1.02; 1.04)
Burkhard, 2006 ^183^ | 536 | Age | 0.96 (0.90; 1.02)
Age (stress)
Maral, 2001 ^645^ | 1,000 | Age 45–54 vs. 35–44 | 1.40 (0.14; 13.98)
| 1,000 | Age 55–64 vs. 35–44 | 4.54 (0.60; 39.61)
| 1,000 | Age >65 vs. 35–44 | 6.03 (0.80; 52.90)
Age (urge)
Ueda, 2000 ^74^ | 968 | Age 60–69 | 2.16 (0.90; 5.17)
| 968 | Age 70–79 | 5.34 (2.26; 12.62)
Nuotio, 2002 ^578^ | 171 | Age (Per year) | 1.01 (0.95; 1.08)
Race (total)
Hu, 2003 ^175^ | 12,079 | Nonwhite vs. white | 0.88 (0.72; 1.07)
Coffee (total)
Bortolotti, 2000 ^72^ | 748 | Coffee cups/day 1 vs. 0 | 0.30 (0.10; 1.00)
| 683 | Coffee cups/day 2 vs. 0 | 0.30 (0.10; 0.70)
| 1,198 | Coffee cups/day 3+ vs. 0 | 0.70 (0.20; 2.00)
Education (total)
Bortolotti, 2000 ^72^ | 748 | Education secondary vs. primary education | 0.90 (0.40; 1.80)
Schmidbauer, 2001 ^83^ | 1,236 | Secondary or higher education vs. primary | 1.57* (0.92; 2.68)
Van Oyen, 2002 ^92^ | 3,462 | Higher education vs. primary | 0.76 (0.42; 1.35)
Physical activity (total)
Schmidbauer, 2001 ^83^ | 1,236 | Physical activity 1+/week vs. none | 0.49* (0.25; 0.96)
Van Oyen, 2002 ^92^ | 3,462 | <4hours/week of physical activity vs. training | 1.85 (0.76; 4.46)
| 3,462 | Sedentary life vs. training | [underlined: 2.70 (1.12; 6.48)]
Marital status (total)
Muscatello, 2001 ^84^ | 232 | Single vs. married | 1.90 (0.90; 4.20)
| 232 | Never married vs. married | 1.50 (0.70; 3.60)

Bold - adjusted odds ratios;

* relative risk;

underlined - significant association at 95% confidence level

Alcohol intake (Figure 19) ^72,^ ^83,^ ^84,^ ^92^ did not show an association with male UI. Only one study of 748 men 61–70 years old showed that 15–21 alcoholic drinks weekly were associated with lower adjusted odds of urine loss during the last year). ^72^ Three studies examined crude and adjusted odds of UI among smokers and none found a significant association (Figure 20). ^72,^ ^83,^ ^92^

Figure 19. Association between alcohol intake and male UI

Figure 20. Association between smoking and male UI

BMI in relation to UI was examined in two studies with univariate ^79,^ ^92^ and three studies with multivariate ^72,^ ^83,^ ^84^ analysis (Figure 21). Only one study of 232 males reported an increase in adjusted odds of total UI by 320 percent among obese males. ^84^ Males with diabetes had significantly higher adjusted rates of UI in two ^97,^ ^176^ studies of five ^58,^ ^72,^ ^86,^ ^97,^ ^176^ with pooled odds ratio of 1.4 (95 percent CI 1.1;1.6) (Figure 22).

Figure 21. Association between BMI and male UI

Figure 22. Association between diabetes and male UI (random effects model)

Comorbidities and poor general health were associated with UI in several studies (Table 21). ^81,^ ^84,^ ^92,^ ^97^ The presence of FI was associated with an increased odds of urge UI in one study of 2,198 males (OR 17, 95 percent CI 7.5; 40) ^176^ but with random changes in another. ^106^ Males with arthritis had higher adjusted odds of total ^86^ (OR1.6, 95 percent CI 1.1; 2.4) or urge UI (OR 1.8, 95 percent CI 1.4; 2.4). ^176^

Table 21 Association between risk factors and male UI

Author | Sample | Risk Factor | Relative Measure of Association (95% CI)
Muscatello, 2001 ^84^ | 232 | Self reported poor health | [underlined: 4.70 (1.90; 11.40)]
Maggi, 2001 ^81^ | 867 | Self-rated health | 1.69 (1.00; 2.88)
Nakanishi, 1997 ^58^ | 1,405 | Poor general health | [underlined: 3.18 (1.72; 5.89)]
Schmidbauer, 2001 ^83^ | 1,236 | Systolic blood pressure >146 vs. <145 | 0.81 (0.44; 1.49)
| | Diastolic blood pressure >90 vs. <90 | 1.23 (0.67; 2.27)
Finkelstein, 2002 ^86^ | 25,400 | Hypertension | 1.88 (0.81; 4.36)
| | Heart problems | 1.01 (0.58; 1.76)
Landi, 2003 ^97^ | 2,178 | Heart failure | 1.06 (0.79; 1.41)
| | Atrial fibrillation | 1.11 (0.82; 1.52)
Ueda, 2000 ^74^ | 968 | Angina | 2.76
Koskimaki, 2001 ^176^ | 2,198 | Hypertension | 1.2* (0.90; 1.60)
| | Heart disease | 1.2* (0.90; 1.70)
Van Oyen, 2002 ^92^ | 3,462 | Comorbidity | 1.67 (0.80; 3.49)
| | Comorbidities | 3.85 (1.98; 7.51)
| | Comorbidity | 1.33 (0.60; 2.94)
| | Comorbidities | [underlined: 2.65 (1.28; 5.52)]
Maggi, 2001 | 867 | Constipation | 0.76 (0.35; 1.70)
| | Diarrhea | [underlined: 6.92 (2.22; 21.50)]
| | Comorbidity | 1.52 (0.89; 2.61)
Finkelstein, 2002 ^86^ | 25,400 | Back problems | [underlined: 2.10 (1.50; 2.93)]
Landi, 2003 ^97^ | 2,178 | Hip fracture | 1.06 (0.74; 1.51)
| | Constipation | 1.10 (0.86; 1.41)
Ueda, 2000 ^74^ | 968 | Constipation | 0.762* (0.35; 1.66)
Nuotio, 2003 ^106^ | 171 | Comorbidity | 1.40 (0.66; 2.93)
Stenzelius, 2004 ^114^ | 1,642 | Edema in legs | [underlined: 1.32 (1.11; 1.58)]
| | Diarrhea | [underlined: 0.66 (0.50; 0.88)]
| | Dizziness | [underlined: 1.26 (1.07; 1.50)]
| | Fatigue | [underlined: 1.21 (1.02; 1.44)]
Koskimaki, 2001 ^176^ | 2,198 | Lower back pain | 1.6* (1.00; 2.30)
| | Constipation | 1.3* (0.80; 2.20)
| | Inguinal hernia | 1.9* (0.90; 4.00)
Landi, 2003 ^97^ | 2,178 | CPS score 2–4 vs. 0–1 | [underlined: 2.04 (1.61; 2.58)]
| | CPS score >5 vs. 0–1 | [underlined: 5.37 (3.90; 7.38)]
Nuotio, 2003 ^106^ | 171 | Fecal incontinence | 3.50 (0.24; 50.37)
Koskimaki, 2001 ^176^ | 2,198 | FI | [underlined: 17* (7.50; 40.00)]
Finkelstein, 2002 ^86^ | 25,400 | Arthritis | [underlined: 1.59 (1.07; 2.38)]
Nelson, 2005 ^4^ | 2,559 | Arthritis | 0.80 (0.70; 1.00)
Koskimaki, 2001 ^176^ | 2,198 | Arthritis | [underlined: 1.8* (1.40; 2.40)]
| | Rheumatoid arthritis | 1* (0.40; 2.70)
Nakanishi, 1997 ^58^ | 1,405 | Dementia | 2.71 (0.41; 17.96)
Nelson, 2005 ^4^ | 2,559 | Dementia | [underlined: 1.50 (1.20; 1.70)]
Schmidbauer, 2001 ^83^ | 1,236 | Feeling stressed | 0.86 (0.45; 1.63)
Muscatello, 2001 ^84^ | 232 | High stress | 1.80 (0.70; 4.40)
Nuotio, 2003 ^106^ | 171 | Low social activity | 1.29 (0.61; 2.75)
| | Depressive mood | [underlined: 2.69 (1.14; 6.34)]
Nakanishi, 1997 ^58^ | 1,405 | No participation in social activity | 1.10 (0.55; 2.21)
| | No life worth living | 1.29 (0.66; 2.53)
| | Anxiety | 1.55 (0.78; 3.05)
Bortolotti, 2000 ^72^ | 748 | BPCO | 1.70 (0.70; 4.00)
Finkelstein, 2002 ^86^ | 25,400 | Asthma | 1.30 (0.73; 2.32)
| | COPD | 1.33 (0.74; 2.40)
Stenzelius, 2004 ^114^ | 1,642 | Protracted coughing | [underlined: 1.33 (1.04; 1.69)]
Koskimaki, 2001 ^176^ | 2,198 | Pulmonary disease | 1.3* (0.90; 1.90)
Smoger, 2000 ^181^ | 840 | Use of antispasmodic agents | 3.11 (1.00; 9.96)
| | diuretics | 1.20 (0.84; 1.69)
Van Oyen, 2002 ^92^ | 3462 | Diuretics | [underlined: 2.24 (1.07; 4.67)]
Finkelstein, 2002 ^86^ | 25,400 | Pain medication | 0.77 (0.52; 1.15)
| | Tranquilizers | 1.16 (0.58; 2.35)
| | Antidepressants | 1.79 (1.00; 3.23)
| | Hypnotics | 1.09 (0.65; 1.84)
| | Narcotics | [underlined: 2.03 (1.28; 3.20)]
| | Laxatives | [underlined: 2.34 (1.46; 3.75)]
| | Asthma medication | 1.55 (0.84; 2.87)
| | BP medication | 0.45 (0.20; 1.00)
| | Heart medication | 1.38 (0.81; 2.35)
| | Diuretics | [underlined: 2.11 (1.28; 3.47)]
| | Antibiotics | 1.11 (0.74; 1.66)
Nuotio, 2003 ^106^ | 171 | Polypharmacy | 1.55 (0.68; 3.50)
| | Sleeping medication | 0.70 (0.30; 1.62)

* urge UI; italic - relative risk;

bold - adjusted odds ratios;

underlined - significant association at 95% confidence level

Dementia was associated with an increase adjusted odds of UI in nursing home male residents ^4^ but not in community dwelling older men in Japan. ^58^ The National Population Health Survey in Canada reported that use of narcotics, laxatives, and diuretics were associated with greater odds of UI independent of other risk factors. ^86^ Memory problems, epilepsy, and neurological diseases were associated with higher rates of UI (Figure 23). ^4,^ ^58,^ ^72,^ ^86,^ ^97,^ ^176^ – ^178^ Stroke was shown as a strong and independent risk factor for UI (Figure 24) in nursing home residents ^4^ and in community dwelling males ^58,^ ^86,^ ^97,^ ^176,^ ^177^ with a pooled odds ratio of 2.12 (95 percent CI 1.36; 3.29). Restrictions in activities of daily living were associated with higher crude and adjusted odds of UI in males in all studies that examined the relationship (Figure 25). ^4,^ ^81,^ ^92,^ ^97,^ ^106,^ ^114^

Figure 23. Association between neurological diseases and male UI

Figure 24. Association between stroke and male UI

Figure 25. Association between ADL and male UI

Males with urinary tract infections had higher adjusted rates of UI (Figure 26) with a pooled odds ratio of 3.5 (95 percent CI 2.3; 5.2). ^72,^ ^74,^ ^92,^ ^97,^ ^106^ Acute genitourinary toxicity, enuresis, incomplete urination, and other urological conditions were associated with higher adjusted odds of UI in all studies that examined the relationship (Figure 27). ^72,^ ^170,^ ^174,^ ^179^

Figure 26. Association between urinary tract infections and symptoms and male UI

Figure 27. Association between urinary tract conditions and male UI

Men with prostate diseases had higher rates of UI after adjustment for confounding factors in the majority of the studies (Figure 28). ^72,^ ^83,^ ^92,^ ^170,^ ^176,^ ^180^ – ^183^ Prostate cancer (RR 2 95 percent, CI 1.5; 2.8), radical prostatectomy (RR 4.3, 95 percent CI 2.6; 7.3), and radiotherapy for prostate cancer (RR 2.3, 95 percent CI 1.3; 4.1) were associated with increased adjusted relative risk of UI. ^180^

Figure 28. Association between prostate diseases, treatments for prostate disease, and male UI

PC - prostate cancer; RP - radical prostatectomy, TURP - transurethral resection of prostate; PSA - prostate specific antigen; NVB - neurovascular bundle resection

### Summary

Consistent published evidence, Level IIb-III suggested that poor general health, limitation in daily activities, stroke, diabetes, and treatments for prostate cancer were associated with higher risk of UI in men.

### Association between Stroke and UI in Community Dwelling Adults

Acute stroke was associated with a 280–520 percent higher prevalence of UI compared to age-matched adults without stroke. ^177^ The prevalence of UI among patients with acute stroke varied from 7 percent ^646^ to more than 30 percent ^220,^ ^647^ – ^649^ (Table 22). The prevalence varied depending on definitions of UI from 11 percent for partial to 36 percent for complete UI. ^220^ One study reported the incidence of UI in patients with stroke as 2 percent for women and 4 percent for men. ^650^ The prevalence decreased with the time of followup after an acute stroke (11 to 36 percent) to 8 to 11 percent at 6 months. ^220^ Elderly patients experienced UI more often, from 35 percent in younger patients to 57 percent among those older than 80 years (Table 23). ^647^ The adjusted odds of UI remained higher 4 years after stroke. ^177^ Age was associated with increased risk of UI among patients with stroke by 72 percent per 10 years. ^220^ The results, however, were not consistent across the studies, with 16 times greater odds of UI after 75 years of age in one study ^651^ but an association in the opposite direction in another. ^652^ Functional impairment after stroke including dysphasia, dysphagia, visual field defect, motor weakness, and cognitive impairment was associated with significant increase in UI. ^177,^ ^651^ – ^653^

Table 22 Prevalence of UI in patients with stroke

Author | Patient Population | UI | Sample Size | Prevalence (% CI)
Nakayama, 1997 ^220^ | Acute stroke patients from The Copenhagen Stroke Study | Full UI | 935 | 36
| Acute stroke patients from The Copenhagen Stroke Study | Partial UI | 935 | 11
| At discharge | Full UI | 935 | 15
| | Partial UI | 935 | 13
| At 6-Month Followup | Full UI | 935 | 8
| | Partial UI | 935 | 11
| Full UI on Admission | Full UI at discharge | 935 | 30
| | Partial UI at discharge | 935 | 10
| | Full UI 6 at month followup | 935 | 14
| | Partial UI at 6 month followup | 935 | 10
Di Carlo, 1999 ^647^ | Acute first-in-a-lifetime stroke (European Union Concerted Action) | UI in <80 years | 3,141 | 34.9
| | UI in >80 years | 1,358 | 57.4
| | UI | 4,499 | 41.7
Hankey, 2000 ^648^ | Acute cerebrovascular disease in the Perth Community Stroke Study | UI | 492 | 43.6
Lawrence, 2001 ^649^ | Acute first-in-a-lifetime in the South London Stroke Register | UI | 1,259 | 48.2
| Total anterior circulation infarcts | UI | 189 | 87 (82; 92)
| Partial anterior circulation infarcts | UI | 250 | 37 (31; 43)
| Posterior circulation infarcts | UI | 142 | 38 (30; 45)
| Lacunar infarcts | UI | 283 | 25 (20; 30)
| Primary intracerebral hemorrhage | UI | 170 | 70 (63; 78)
| Subarachnoid hemorrhage | UI | 77 | 71 (57; 85)
Paolucci, 2001 ^656^ | Survivors after the first stroke. | UI | 178 | 15.7
| UNILATERAL SPATIAL NEGLECT | UI | 178 | 44.9
| Survivors after the first stroke. | UI at discharge | 178 | 4.9
| UNILATERAL SPATIAL NEGLECT | UI at discharge | 178 | 20.5
Patel, 2011 ^651^ | Acute first-in-a-lifetime in the South London Stroke Register | UI | 235 | 40
| 3 month followup | UI | 235 | 19
| 1 year followup | UI | 235 | 15
| 2 year followup | UI | 235 | 10
van Kuijk. 2001 ^651^ | Survivors after first-time, unilateral hemispheric stroke | Incident UI | 143 | 2.9 (1.8; 4.8)
| | Incident UI in Women | 143 | 1.7 (0.6; 45)
| | Incident UI Men | 143 | 3.9 (2.2; 6.9)
| | Regained continence rate | 143 | 14.6 (7.3; 29.2)
Lee, 2003 ^646^ | Subarachnoid haemorrhage | UI | 322 | 3.1
| Intracerebral haemorrhage | UI | 322 | 5.2
| Ischemic stroke | UI | 322 | 6.7
| transient ischemic attack | UI | 322 | 2

Table 23 Association between stroke and UI in community dwelling adults

Author | Age | Risk Factors | Odds Ratio (95% CI)
Sample
Nakayama, 1997 ^220^ | 74.6 | Age for 10-year increments | 1.72 (1.32; 2.25)
N = 935; 60% female | | Lesion size for a 10-mm increase in diameter | 1.22 (1.1; 1.36)
| | DM | 3.38 (1.75; 6.51)
| | Hypertension | 0.5 (0.29; 0.87)
| | Other disabling disease | 2.4 (1.28; 4.52)
| | Initial Scandinavian Stroke Scale score - 10-point increase in SSS score | 0.39 (0.3; 0.45)
Patel, 2001 ^651^ | 73.3 | <50 | 1
N = 235; 50% female | | 50–75 | 6.14 (0.97; 38.89)
| | >75 | 15.9 (2.18; 116.17)
| | Female sex | 0.84 (0.39; 1.8)
| | Total Anterior Circulatory Infarction | 1
| | Partial Anterior Circulatory Infarction | 0.36 (0.09; 1.48)
| | Posterior Circulatory Infarction | 0.45 (0.09; 2.4)
| | Lacunar Infarction | 0.12 (0.02; 0.62)
| | Primary Intracerebral hemorrhage | 1.31 (0.24; 7.12)
| | Subarachnoid hemorrhage | 15.4 (1.32; 179.8)
| | Unknown | 0.83 (0.12; 5.85)
| | Hypertension | 0.76 (0.35; 1.65)
| | Diabetes mellitus | 0.93 (0.31; 2.8)
| | Atrial fibrillation | 1.4 (0.53; 3.68)
| | Dysphasia | 2.04 (0.76; 5.47)
| | Dysphagia | 4.03 (1.85; 8.73)
| | Visual field defect | 4.78 (1.78; 12.9)
| | Motor weakness | 5.41 (1.38; 21.1)
Patel, 2001 ^652^ | 73.1 | >75 | 0.38 (0.17; 0.83)
N = 207; 42% female | | Female sex | 0.71 (0.34; 1.47)
| | Total anterior circulation infarcts | 1
| | Partial anterior circulation infarcts | 2.22 (0.78; 6.37)
| | Posterior circulation infarcts | 2.24 (0.43; 11.6)
| | Lacunar infarcts | 3.66 (1.1; 12.2)
| | Primary intracerebral hemorrhage | 1.42 (0.5; 4.03)
| | Subarachnoid hemorrhage | 0.6 (0.09; 4.13)
| | Unknown | 3.78 (0.48; 29.7)
| | Hypertension | 0.64 (0.31; 1.3)
| | Diabetes mellitus | 1.23 (0.47; 3.22)
| | Atrial fibrillation | 1.03 (0.45; 2.33)
| | Motor weakness | 1.23 (0.27; 5.56)
| | Dysphasia | 1.45 (0.65; 3.22)
| | Dysphagia | 0.77 (0.35; 1.71)
| | Barthel index 0–14 | 1
| | Barthel index 15–18 | 21.8 (5.95; 79.7)
Tang, 2004 ^653^ | 70.9 | Poststroke dementia | 6.7 (3.5; 12.8)
N = 280; 45% female
Jorgensen, 2005 ^177^ | | Stroke | 2.8 (1.5; 5.2)
N = 213/242 | | Acute stroke (<1 year) | 5.2 (1.6; 17.2)
noninstitutionalized stroke survivors and healthy control | | 1–4 Years after stroke | 5.3 (2.3; 12.6)
| | 5–10 Years after stroke | 2.2 (1; 5)
| | > 10 years after stroke | 1.4 (0.5; 4.1)
| | Weakness of a leg (SSS score, <5), or depressive symptoms (MADRS score, >7), or lower cognitive function (MMSE score<24) | 3.5 (1.5; 8.2)
| | 2–3 of weakness of a leg (SSS score, <5), or depressive symptoms (MADRS score, >7), or lower cognitive function (MMSE score<24) | 7.2 (2.1; 24.6)

Bold - significant at 95% confidence level

### Risk Factors for UI in LTC Settings

#### Association between risk factors and UI in LTC settings

The prevalence of UI increased with the length of stay in nursing homes from 39 percent at 2 weeks to 44 percent at 1 year after admission. ^28^ It is not clear if this is an effect of prolonged exposure or a difference in case mix (Table 24). The majority of residents with cognitive impairment experienced UI (72 to 84 percent). ^1^ The proportion of incontinent patients increased responding to severity of impairment, from 60 percent in mild to 93 percent in severely demented. ^34^ Physical dependency was associated with a higher prevalence of UI, from 26 percent in independent residents to 81 percent immobile. ^34^ The prevalence of UI among dependent residents was more than 70 percent in seven countries and varied from 87 percent in Iceland to 72 percent in the United States. ^1^ The prevalence of UI among residents with diabetes ranged from 55 percent ^29^ to 65 percent. ^34^ Almost all (93 percent) residents with FI also experienced UI. ^29^ One study of 9,013 patients with multiple sclerosis reported 21 percent UI and 9 percent of frequent UI. ^654^ The estimations were not consistent; however, the prevalence of UI among patients with urinary tract infection in Italy was 63 percent in one study ^1^ and 81 percent in another. ^29^ Few studies examined adjusted odds ratios of UI among residents in LTC independent of other confounding factors. Aging was associated with increased odds of UI by 3 percent per year to 24 percent per 5 years of age (Table 25). ^4,^ ^165^ In contrast with higher incidence of UI in males, ^166^ prevalence of UI was lower in males than females in two studies ^29,^ ^165^ of three ^29,^ ^165,^ ^655^ that examined this association. Race, BMI, diabetes, arthritis, and cardiovascular diseases did not show significant association with UI, but the evidence was limited to one state survey of nursing homes. ^4,^ ^165^

Table 24 Prevalence of UI among residents in LTC with risk factors

Author | Country | Risk Factor | Sample | Prevalence (%)
Cognitive Impairment
Borrie, 1992 ^34^ | UK | No mental impairment | 140 | 27
| | Mild mental impairment | 96 | 60
| | Moderate mental impairment | 78 | 86
| | Severe mental impairment | 123 | 93
| | Dementia | 139 | 78
Sgadari, 1997 ^1^ | | Denmark, impaired cognitive status | 1,799 | 72.4
| | France, impaired cognitive status | 167 | 81.4
| | Iceland, impaired cognitive status | 377 | 78.9
| | Italy, impaired cognitive status | 586 | 79
| | Japan, impaired cognitive status | 539 | 84
| | Sweden, impaired cognitive status | 436 | 83.9
| | USA, impaired cognitive status | 126,070 | 78.3
Dependency
Borrie, 1992 ^34^ | UK | Independent | 110 | 26
| | Supervised | 33 | 52
| | Assistance required | 59 | 69
| | Immobile | 233 | 81
Sgadari, 1997 ^1^ | | Denmark, dependent | 1,799 | 81.2
| | Denmark, bedfast | 1,799 | 69.3
| | France, dependent | 167 | 83.5
| | France, bedfast | 167 | 82.5
| | Iceland, dependent | 377 | 79.1
| | Iceland, bedfast | 377 | 86.6
| | Italy, dependent | 586 | 82.7
| | Italy, bedfast | 586 | 82.5
| | Japan, dependent | 539 | 80.8
| | Japan, bedfast | 539 | 79.5
| | Sweden, dependent | 436 | 87
| | Sweden, bedfast | 436 | 57.9
| | USA, dependent | 126,070 | 71.5
| | USA, bedfast | 126,070 | 61.9
Internal Diseases
Borrie, 1992 ^34^ | UK | Diabetes | 51 | 65
| | Malignant neoplasm | 34 | 44
| | Cerebrovascular diseases | 113 | 70
| | Parkinson's disease | 40 | 78
| | Multiple sclerosis | 25 | 60
| | COPD | 52 | 42
| | Prostate disease | 28 | 79
| | Ischemic heart disease | 58 | 64
| | Hypertension | 40 | 65
Aggazzotti, 2000 ^29^ | Italy | Diabetes | 121 | 55.4
| | Constipation | 253 | 72.7
| | Fecal incontinence | 196 | 93.4
| | Neurological disease | 322 | 71
| | Bone fracture | 21 | 52.4
| | Urinary tract infection | 79 | 81
| | Psychiatric disease | 89 | 29
| | Hypertension | 330 | 58
| | Cardiovascular diseases | 82 | 46
Buchanan, 2001 ^654^ | USA | Multiple sclerosis | 9,013 | 21.3
| | Multiple sclerosis, occasional UI | 9,013 | 5.6
| | Multiple sclerosis, frequent UI | 9,013 | 9
Sgadari, 1997 ^1^ | | Denmark, urinary tract infection | 1,799 | 68.4
| | France, urinary tract infection | 167 | 77.8
| | Iceland, urinary tract infection | 377 | 56.4
| | Italy, urinary tract infection | 586 | 62.7
| | Japan, urinary tract infection | 539 | 54
| | Sweden, urinary tract infection | 436 | 80.9
| | USA, urinary tract infection | 126,070 | 50.9
LOS
Palmer, 1991 ^28^ | USA | 2 weeks after admission | 434 | 39
| | 2 months after admission | 317 | 47
| | 1 year after admission | 196 | 44

Table 25 Association between UI and risk factors (adjusted odds ratios) in LTC settings

Author | Age | Sample | Gender % Female | Odds Ratio (95% CI)
Age
Nelson, 2005 ^4^ | 85.9 | 3,850 | 71 | 1.03 (1.02; 1.04)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 0.99 (0.98; 0.99)
| | | | 0.98 (0.98; 0.99)
Aggazzotti, 2000 ^29^ | 82 | 839 | 59.8 | 1.24 every 5 years
| | | | (1.02; 1.51)
Saxer, 2005 ^655^ | | 2,722 | 67 | 0.43 - Age 65 to 74 vs. >95
| | | | (0.19; 0.95)
| | | | 0.62 – 75 to 84 vs. >95
| | | | (0.32; 1.21)
| | | | 0.64 – 85 to 94 vs. >95
| | | | (0.34; 1.23)
Male Gender
Nelson, 2005 ^4^ | 85.9 | 3,850 | 71 | 0.8 (0.7; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 0.8 (0.7; 0.9)
| | | | 0.8 (0.7; 0.8)
Aggazzotti, 2000 ^29^ | 82 | 839 | 59.8 | 0.51 (0.81; 0.33)
Saxer, 2005 ^655^ | | 2,722 | 67 | 1.69 (1.36; 2.09)
Race (NW = 1, W = 0)
Nelson, 2005 ^4^ | 85.9 | 3,850 | 71 | 1 (1; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 1 (1; 1)
| | | | 1 (1; 1)
BMI
Nelson, 2005 ^4^ | 85.9 | 3,850 | 71 | 1 (1; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 1 (1; 1)
| 85.9 | 10,328 | 71 | 1 (1; 1)
Diabetes
Nelson, 2005 ^4^ | 85.9 | 3,850 | 71 | 1 (1; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 1 (1; 1)
| | | | 1 (1; 1)
CVD
Nelson, 2005 ^4^ | 85.9 | 3,850 | 71 | 1 (1; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 1 (1; 1)
| | | | 1 (1; 1)
Stroke
Nelson, 2005 ^4^ | 85.9 | 3850 | 71 | 1.2 (1; 1.5)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 1.3 (1.2; 1.4)
| | | | 1.4 (1.2; 1.5)
Arthritis
Nelson, 2005 ^4^ | 85.9 | 3850 | 71 | 0.8 (0.7; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | 1 (1; 1)
| | | | 1 (1; 1)

Bold - significant association at 95% confidence level.

Stroke increased the adjusted odds of UI by 20 to 40 percent. ^4,^ ^165^ Physical dependency was a strong and independent risk factor for UI in several studies (Table 26). ^4,^ ^29,^ ^164,^ ^165^ Impairment of ADLs was associated with three to four times larger odds of UI. ^4,^ ^164^ Residents with dependency in toilet use experienced UI six times more often. ^165^ The odds of UI were seven times higher among wheelchair users and bedridden residents. ^29^ Mental impairment was associated with 192 to 361 percent higher prevalence of UI. ^29^

Table 26 Association between dependency, mental, gastrointestinal diseases, and UI (adjusted odds ratios) in LTC settings

Author | Age | Sample | % Female | Risk Factor | OR (95% CI)
Dependency
Nelson, 2005 ^4^ | 85.9 | 3,50 | 71 | Trunk restraints | 2.9 (2; 4.1)
| | | | Impaired vision | 1 (1; 1)
| | | | Pressure ulcer | 1 (1; 1)
| | | | Tube feeding | 1 (1; 1)
| | | | Loss of ADL | 3.1 (2.6; 3.8)
| | 951 | | Toilet use | 1 (1; 1)
| | | | Eating | 1.3 (1.1; 1.6)
| | | | Hygiene | 1.7 (1.3; 2.1)
| | | | Dressing | 1.8 (1.5; 2.3)
| | | | Bed mobility | 1 (1; 1)
| | | | Locomotion | 1.3 (1.1; 1.5)
| | | | Transferring | 1 (1; 1)
Brandeis, 1997 ^164^ | 60–105 | 2,14 | 75.5 | Impairment of ADL | 4.2 (3.2; 5.6)
| | | | Restraints: Trunk | 1.7 (1.5; 2)
| | | | Restraints: Chair | 1.4 (1.2; 1.6)
| | | | Restraints: Bedrails | 1.3 (1.1; 1.5)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | Trunk restraints | 2.5 (2.3; 2.8)
| | | | Impaired vision | 1.4 (1.3; 1.5)
| | | | Pressure ulcer | 1 (1; 1)
| | | | Tube feeding | 0.6 (0.4; 0.7)
| | | | Trunk restraints | 2.4 (2.1; 2.7)
| | | | Impaired vision | 1.4 (1.3; 1.6)
| | | | Pressure ulcer | 1 (1; 1)
| | | | Tube feeding | 0.7 (0.5; 0.9)
| | | | Dependency in toilet use, 1992 | 5.6 (4.9; 6.6)
| | | | Dependency in eating, 1992 | 3 (2.8; 3.3)
| | | | Dependency in hygiene, 1992 | 2 (1.7; 2.5)
| | | | Dependency in dressing, 1992 | 1 (1; 1)
| | | | Dependency in bed mobility, 1992 | 1.8 (1.6; 1.9)
| | | | Dependency in locomotion, 1992 | 1.2 (1.1; 1.3)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | Dependency in transferring, 1992 | 1 (1; 1)
| | | | Dependency in toilet use, 1993 | 6.3 (5.3; 7.4)
| | | | Dependency in eating, 1993 | 2.9 (2.7; 3.2)
| | | | Dependency in hygiene, 1993 | 1.8 (1.5; 2.3)
| | | | Dependency in dressing, 1993 | 1 (1; 1)
| | | | Dependency in bed mobility, 1993 | 1.9 (1.7; 2.1)
| | | | Dependency in locomotion, 1993 | 1.2 (1.1; 1.3)
| | | | Dependency in transferring, 1993 | 1 (1; 1)
Aggazzotti, 2000 ^29^ | 82 | 839 | 59.8 | Mobility With support | 1.8 (1.5; 3.0)8
| | | | Mobility with care providers | 5.63 (2.92; 10.8)
| | | | Wheelchair/bedridden | 7.38 (4.86; 11.2)
Saxer, 2005 ^655^ | | 2722 | 67 | No loss in long-term memory | 0.7 (0.54; 0.9)
| | | | Cognitive abilities | 0.64 (0.49; 0.83)
| | | | No problem moving in bed | 0.51 (0.36; 0.73)
| | | | No problem moving around among 65–74 years | 0.33 (0.07; 1.57)
| | | | No problem moving around among-84 | 0.28 (0.11; 0.75)
| | | | No problem moving around among 85–94 | 0.63 (0.25; 1.61)
| | | | Minor problem moving around among 65–74 | 0.74 (0.15; 3.68)
| | | | Minor problem moving around among 75–84 | 1.02 (0.37; 2.83)
| | | | Minor problem moving around among 85–94 | 1.1 (0.41; 2.93)
| | At 12 months | | No loss in long-term memory | 0.19 (0.08; 0.46)
| | | | No problem moving in bed | 0.17 (0.06; 0.48)
| | | | No problem moving about in own corridor | 0.15 (0.03; 0.67)
| | | | no problem moving in bed | 0.13 (0.03; 0.55)
| | At 12 months adjusted for baseline condition | | No loss in long-term memory | 0.53 (0.36; 0.78)
| | | | No problem walking in room | 0.34 (0.18; 0.63)
Gastrointestinal Diseases
Nelson, 2005 ^4^ | 85.9 | 3850 | 71 | Constipation | 1 (1; 1)
| | | | Fecal impaction | 1 (1; 1)
| | | | Diarrhea | 1 (1; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | Fecal incontinence | 20.5 (18.6; 22.6)
| | | | Constipation | 1.3 (1.2; 1.4)
| | | | Fecal impaction | 1 (1; 1)
| | | | Diarrhea | 0.7 (0.5; 0.8)
| | | | Fecal incontinence | 17.8 (16.1; 19.7)
| | | | Constipation | 1.3 (1.2; 1.4)
| | | | Fecal impaction | 1 (1; 1)
| | | | Diarrhea | 0.7 (0.6; 0.9)
Aggazzotti, 2000 ^165^ | 82 | 839 | 59.8 | Fecal incontinence | 10.4 (1.4; 20.2)
Mental Diseases
Nelson, 2005 ^165^ | 85.9 | 3850 | 71 | Depression | 1 (1; 1)
Brandeis, 1997 ^165^ | 60–105 | 2014 | 75.5 | Use of anti anxiety/hypnotics | 0.7 (0.5; 1)
Nelson, 2001 ^165^ | 85.9 | 10,328 | 71 | Depression, 1992 | 1 (1; 1)
| | | | Depression, 1993 | 1 (1; 1)
Aggazzotti, 2000 ^165^ | 82 | 839 | 59.8 | Alternating mental orientation | 1.92 (1.08; 3.44)
| 82 | 839 | 59.8 | No mental orientation | 3.61 (2.42; 5.39)

Bold - significant associations at 95% confidence level.

FI was associated with ten ^29^ to 20 ^165^ times larger odds of UI. The conditions that assume intensive bowel control and frequent checking of wet condition of residents, including tube feeding and diarrhea, were associated with lower UI. In conclusion, consistent evidence suggests that restrictions in ADL, physical dependency, and cognitive impairment are risk factors for UI in LTC. Factors that induce UI also seem to affect FI.

### Overview of Risk Factors for FI

#### Age

In the past decade, a large body of evidence has suggested an association between FI and patient age. Age was a strong predictor of FI and combined UI and FI in the majority of the studies (79 percent or 22/28) (Table 27). The association between age and FI was examined among women only. ^187,^ ^208^ – ^213^ Adjusted odds of AI increased by 87 percent for every additional 10 years of age in Asian women and by 36 percent in White women. ^187^ The frequent comorbidity of FI and UI may be attributable to the common cause of both disorders, such as pelvic floor sphincter injuries. ^4,^ ^58,^ ^162,^ ^186^ Women over age 42 reported combined UI and FI 16 times more often than younger females after adjustment for other risk factors. ^186^ Japanese adults over age 75 had 319 percent higher odds of combined UI and FI compared to those 65–74 years old. ^58^ The association between age and FI was not linear. ^657^ However, one study reported a 30 percent increase in the adjusted odds of FI corresponding to a 10 year increment in age in women. ^225^ The threshold age for women was related to menopausal age; no significant increase in FI was shown when women older than 30 or 35 years were compared to women younger than 29 years of age. ^230^ The results became significant when 30–49 year old women were compared to those 50–69 years old (211 percent increase in FI) or those 70–90 years old (222 percent increase in FI). ^163^ No studies reported adjusted odds ratios of FI in men, with an inconsistent increase in the crude odds of FI after 35, ^658^ 44, ^659^ or 65 years of age. ^221^ Studies with women and men analyzed together reported a 2 percent increase in FI in adults older than 40 years ^222^ and a 271 percent increase in FI after age 75 ^58^ after adjustment for other risk factors.

Table 27 Association between age and FI

Author | Definition of FI | Gender | Age as a Risk Factor (strata with cut offs) | Odds Ratio (95% CI)
Sample
Richter, 2005 ^208^ | AI | Women only | Age | 1.02 (0.98; 1.05)
N = 180
Pollack, 2004 ^209^ | AI | Women only | Age | 1.10 (1.00; 1.20)
N = 349
Ng, 2002 ^210^ | AI | Women only | >65 | 1.77 (0.33; 9.41)
N = 320
Meschia, 2002 ^211^ | AI | Women only | Age | 1.30 (0.80; 2.00)
N = 881
Boreham, 2005 ^212^ | AI | Women only | Age (per year) | 1.05 (1.03; 1.07)
N = 457
Chen, 2003 ^213^ | AI | Women only | > 65 | 0.8 (0.4; 1.8)
N = 1,253
Huang, 2006 ^187^ | AI | Asian women only | Age (per decade) | 1.87 (1.26; 2.79)
| | White women only | Age (per decade) | 1.36 (1.14; 1.61)
Ostbye, 2004 ^186^ | FI+ UI | Men only | 85+ vs. 75–84 | 3.273 (1.02; 10.52)
N = 8,949 | | Men only | 85+ vs. 75–84 | 1.213 (0.36; 4.11)
| | Women only | 85+ vs. 75–84 | 2.37 (0.92; 6.09)
| | Women only | 85+ vs. 75–84 | 1.646 (0.68; 4.0)
| | Men only | 85+ vs. 65–74 | 4.409 (1.20; 16.14)
| | Men only | 85+ vs. 65–74 | 2.064 (0.50; 8.49)
| | Women only | 85+ vs. 65–74 | 4.235 (1.35; 13.26)
| | Women only | 85+ vs. 65–74 | 3.907 (1.24; 12.32)
Nelson, 2005 ^4^ | FI + UI | Combined | Age | 1.02 (1.00; 1.03)
N = 8,170
Ballester, 2005 ^162^ | FI + UI | Women only | >42 | 16.7 (1.9; 141.1)
N = 103
Nakanishi, 1997 ^58^ | FI + UI | Combined | >75 | 3.19 (1.69; 6.04)
N = 1,405i
Quslander, 2005 ^216^ | FI | Combined | >85 vs.65–74 | 3.28 (1.32; 8.16)
N = 6,099 | | Combined | >85 vs.75–84 | 2.00 (0.90; 4.42)
Ostbye, 2004 ^186^ | FI | Women only | 75–84 vs. <65–74 | 1.55 (1.06; 2.26)
N = 8,949 | | Women only | 85+ vs. <65–74 | 1.91 (1.14; 3.17)
| | Women only | 75–84 vs. <65–74 | 1.16 (0.89; 1.51)
| | Women only | 85+ vs. <65–74 | 1.34 (0.87; 2.08)
| | Men only | 75–84 vs. <65–74 | 2.97 (1.64; 5.39)
| | Men only | 85+ vs. <65–74 | 3.41 (1.44; 8.11)
| | Men only | 75–84 vs. <65–74 | 1.25 (0.86; 1.83)
| | Men only | 85+ vs. <65–74 | 2.51 (1.26; 5.01)
| | Men only | 85+ vs. 75–84 | 2.37 (0.86; 6.5)
| | Men only | 85+ vs. 75–84 | 2.25 (0.99; 5.09)
| | Women only | 85+ vs. 75–84 | 1.99 (0.76; 5.21)
| | Women only | 85+ vs. 75–84 | 1.43 (0.62; 3.28)
| | Men only | 85+ vs. 65–74 | 3.59 (1.13; 11.41)
| | Men only | 85+ vs. 65–74 | 4.75 (1.71; 13.23)
| | Women only | 85+ vs. 65–74 | 2.84 (0.97; 8.29)
| | Women only | 85+ vs. 65–74 | 2.35 (0.91; 6.03)
Nelson, 2005 ^4^ | FI | Combined | Age | 1.02 (1.00; 1.03)
N = 8,170
Nelson, 1998 ^3^ | FI | Combined | Age in 1992 | 1.00 (1.00; 1.01)
N = 18,224 | | Combined | Age in 1993 | 1.00 (1.00; 1.01)
Nakanishi 1997 ^58^ | FI | Combined | 75+ vs. 65–74 | 4.1 (2.66; 6.3)
N = 1,405 | | Combined | >75 | 2.71 (1.23; 5.94)
Melville, 2005 ^163^ | FI | Women only | 50–69 vs. 30–49 | 2.11 (1.47; 3.03)
N = 6,888 | | Women only | 70–90 vs. 30–49 | 2.22 (1.47; 3.36)
McKinnie, 2005 ^657^ | FI | Women only | Age (per year) | 1.05 (1.03; 1.07)
N = 1,004 | | Women only | Age (per year) | 1.05 (1.03; 1.07)
Mahony, 2007 ^230^ | FI | Women only | 30–34 vs. ≤29 | 1.20 (0.30; 4.70)
N = 500 | | Women only | >35 vs. ≤29 | 2.70 (0.70; 11.30)
MacArthur, 2001 ^214^ | FI | Women only | Maternal age 25–29 vs. <25 | 1.22 (0.88; 1.69)
N = 7,879r | | Women only | Maternal age 30–34 vs. <25 | 1.71 (1.21; 2.42)
| | Women only | Maternal age > 35 vs. <25 | 1.75 (1.04; 2.94)
Macarthur, 2005 ^215^ | FI | Women only | Maternal age 25–29 vs. <25 | 1.09 (0.84; 1.41)
N = 4,046 | | Women only | Maternal age 30–34 vs. <25 | 1.60 (1.18; 2.16)
| | Women only | Maternal age >35 vs. <25 | 1.72 (1.06; 2.79
Longstreth, 1993 ^659^ | FI | Women only | >65 vs.<44 | 3.60 (2.20; 4.00)
N = 1,264 | | Men only | >65 vs.<44 | 2.00 (0.90; 2.20)
Abramov, 2005 ^226^ | FI | Women only | ≥40 | 2.82 (1.21; 6.6)
N = 542
Ballester, 2005 ^162^ | FI | Women only | >42 | 4.6 (0.9; 22.7)
N = 103
Bharucha, 2006 ^225^ | FI | Women only | Age (per decade) | 1.3 (1.2; 1.4)
N = 2,800
Brittain, 2006 ^222^ | FI | Combined | >40 | 1.02 (1.01; 1.03)
N = 2,800
Chassagne, 1999 ^223^ | FI | Combined | ≥70 | 1.7 (1; 2.8)
Chiarelli, 2003 ^658^ | FI | Men only | >35 | 4.33 (1.56; 12.01)
N = 568
Harari, 2003 ^221^ | FI | Combined | ≥65 | 2.16 (1; 4.8)
N = 1,069
Macarthur, 2005 ^215^ | Persistent FI | Women only | Maternal age 25–29 vs. <25 | 2.61 (1.07; 6.37)
N = 1,793 | | | Maternal age 30–34 vs. <25 | 6.00 (2.42; 14.79)
N = 3,813 | | | Maternal age >35 vs. <25 | 6.00 (1.85; 19.45)
| | | Maternal age 25–29 vs. <25 | 1.12 (0.72; 1.74
| | | Maternal age 30–34 vs. <25 | 1.95 (1.19; 3.19)
| | | Maternal age >35 vs. <25 | 2.65 (1.25; 5.63)
Faltin, 2006 ^695^ | Symptoms ≥2 once/week or 3 symptoms (incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | Women only | Age at followup 45–50 vs. <45 | 1.23 (0.65; 2.3)
N = 540 | | | Age at followup >50 vs. <45 | 2.21 (1.19; 4.1)
Guise, 2007 ^218^ | Severe incontinence, incontinence of stool | Women only | Age at this delivery 20–24.9 vs. <20 | 0.78 (0.54; 1.11)
N = 8,774 | | | Age at this delivery 25–29.9 vs. <20 | 0.78 (0.55; 1.11)
| | | Age at this delivery ≥30 vs. <20 | 0.61 (0.43; 0.86)
| | | Age at 1st delivery 20–24.9 vs. <20 | 0.79 (0.62; 1)
| | | Age at 1st delivery 25–29.9 vs. <20 | 0.74 (0.58; 0.95)
| | | Age at 1st delivery ≥30 vs. <20 | 0.6 (0.46; 0.77)
Hojberg, 2000 ^227^ | Isolated flatus incontinence at least once a week | Combined | 15–24 vs. 25–29 | 0.9 (0.6; 1.3)
| | | Age 30–34 vs. 25–29 | 1.3 (1; 1.8)
| | | Age > 35 vs. 25–29 | 1.6 (1.1; 2.4)
Abramov, 2005 ^226^ | Flatus | Women only | Age ≥40 years | 1.9 (1.11; 3.24)
N = 542

Bold - multivariate odds ratios

Age not only increases the risk of FI, it likely modifies the effects of other risk factors, including birth related anal trauma. Maternal age older than 25 years was associated with greater odds of FI ^214^ and persistent FI. ^215^ Women 20–24 years old at the time of delivery did not experience a larger risk of FI compared to younger pregnant women. ^218^ Less expected was the fact that pregnant women below age 20 experienced FI more often than women over 30. ^218^

The interaction between age and other risk factors requires future research. Pooled analysis indicated that studies with older adults reported higher crude rates of FI, but the estimation had low validity due to significant statistical heterogeneity between studies. ^518^ Age, but not study quality, contributed to differences in rates of FI. ^518^ The authors used different age categories which made pooling more questionable. Pooled analysis of patients' individual data should give better information of the curve-linear association and meaningful cut-points for men and women independent of other risk factors.

#### Gender

This line of research shows mixed results (Table 28). Traditionally, FI is believed to be more prevalent in women. ^6,^ ^622^ Two recent studies confirmed this finding by reporting a greater prevalence of FI in women. ^7,^ ^508^ One study reported greater prevalence of combined incontinence (FI + UI) in community-living elderly women than men. ^660^ However, three different groups of researchers found no differences in the prevalence of FI in women and men. ^4,^ ^216,^ ^217^ Four other studies showed that male gender is an independent risk factor for FI ^3,^ ^58,^ ^222,^ ^224^ and combined incontinence. ^58^ One study indicated that men ages 75–79 or 85–89 are more likely to have FI, combined incontinence, and less severe FI than women in the same group. ^114^ The majority of these studies involved a large sample (more than 4,000) elderly people (>65 years) and adjusted for at least one risk factor. However, a definite association between gender and FI cannot be drawn given varying study designs, sampling and statistical methods, FI definitions, and varying control for potential risk factors. Valid synthesis of different studies would be possible when relative risk of incident incontinence, adjusted for age and gender-specific confounding factors, was examined in prospective cohorts.

Table 28 Association between gender and FI (women as a reference gender)

Author | Definition of FI | Age | Odds Ratio (95% CI)
Sample
Stenzelius, 2004 ^114^ | FI + UI | | 0.70 (0.53; 0.93)
N = 4,277 | | 75–79 | 1.18 (0.84; 1.65)
| | 80–84 | 0.91 (0.66; 1.25)
| | 85–89 | 1.28 (0.89; 1.83)
| | >90 | 0.93 (0.58; 1.47)
Nelson, 2005 ^4^ | FI + UI | | 1.00 (1.00; 1.00)
N = 8,170
Nakanishi, 1997 ^58^ | Fecal I + UI | | 1.61 (0.88; 2.94)
N = 1,405
Stenzelius, 2004 ^114^ | FI | 75–79 | 1.11 0.81; 1.52)
N = 4,277 | | 80–84 | 0.85 (0.63; 1.14)
| | 85–89 | 1.20 (0.85; 1.70)
| | >90 | 0.90 (0.58; 1.40)
Quander, 2005 ^216^ | FI | | 1.00 (1.00; 1.00)
N = 6,099
Nelson, 2005 ^4^ | FI | | 1.00 (1.00; 1.00)
N = 8<170
Nelson, 1998 ^3^ | FI | | 1.20 (1.10; 1.30)
N = 18,244 | | | 1.30 (1.10; 1.40)
Nakanishi, 1997 ^58^ | FI | | 1.33 (0.89; 1.99)
N = 1,405 | | | 1.58 (0.73; 3.41)
Brittain, 2006 ^222^ | FI | | 1.27 (1.05; 1.52)
N = 38,633
Johanson, 1997 ^224^ | FI | | 1.5 (1.1; 1.9)
N = 388
Stenzelius, 2004 ^114^ | FI; a little | 75–79 | 1.23 (0.87; 1.73)
N = 4,277 | FI, very much | 75–79 | 0.78 (0.40; 1.54)
| FI; a little | 80–84 | 0.92 (0.66; 1.28)
| FI; very much | 80–84 | 0.73 (0.40; 1.33)
| FI; a little | 85–89 | 1.17 (0.79; 1.72))
| FI; very much | 85–89 | 1.32 (0.70; 2.46)
| FI; a little | >90 | 0.87 (0.53; 1.44)
| FI; very much | >90 | 1.01 (0.48; 2.12)
Bliss, 2004 ^158^ | Mucus | | 4.5 (1.5; 16.7)
N = 1,352
Johanson, 1997 ^224^ | Solid | | 1.6 (1.2; 2.1)
N = 388

Bold - multivariate odds ratios

#### Race

Limited evidence from one study suggested that Asian women had a higher prevalence of birth related FI compared to other ethnic groups after adjustment for mode of delivery, maternal age, perineal trauma, BMI, and total number of births (Appendix Table F34). ^215^ The prevalence of combined UI and FI was two times higher in non-White than White residents of nursing homes in Wisconsin, independent of other risk factors identified in the Health Care Financing Administration Minimum Data Set. ^4^ Younger Taiwanese women living in the community (mean age of 43 years) had a prevalence of FI of 2.5 percent, ^213^ a rate similar or less than that reported in non-Asian women of a similar age group. ^218,^ ^232^ The association between race and severity of FI and quality of life related to FI in men and women from the community and in LTC facilities requires future investigation.

#### Diet, BMI, and diabetes

The highest prevalence of FI (44 percent) was reported among women with morbid obesity undergoing laparoscopic weight loss surgery (Appendix Table F35). The prevalence of FI among patients with diabetes mellitus varied from 1 percent in women ^163,^ ^211^ to 13 percent in a study of both genders; ^626^ 3 percent of men and women with diabetes experienced incontinence of solid feces and 13 percent solid or liquid feces. ^626^

Adults with decreased serum levels of vitamin B12 (300pg/ml or less) had a significantly higher prevalence of combined UI and FI (Table 29). ^661^ No other dietary intakes have been shown to increase the risk of FI. Increased BMI and the presence of diabetes in residents of nursing homes were not associated with higher rates of combined UI and FI. ^3,^ ^4^ Higher BMI in women did not increase the risk of FI ^208,^ ^210^ – ^213^ but was associated with higher prevalence of flatus ^662^ and liquid feces incontinence. ^185^ One study of 8,774 women reported a 70 percent increase in risk of persistent postnatal FI in obese women (Appendix Table F36). ^218^

Table 29 Association between FI and diet, BMI, and diabetes

Author | Age | Level of Risk Factors in Population Groups | Odds Ratio 95% CI
Sample
BMI
AI in Women
Meschia, 2002 ^211^ | 58.6 | Incremental increase by 1 unit | 1.50 (0.90; 2.30)
N = 881
Richter, 2005 ^208^ | 16–55 | Incremental increase by 1 unit in women with morbid obesity before laparoscopic weight loss surgery | 0.96 (0.92; 1.00)
N = 180
Ng, 2002 ^210^ | | >20, women | 0.93 (0.34; 2.56)
N = 320
Boreham, 2005 ^212^ | 18–64 | Incremental increase by 1 unit | 1.04 (1.01; 1.08)*
N = 457
Chen, 2003 ^213^ | ≥20 | 1^st^ vs. 4^th^ (≤25 percentile) | 0.80 (0.40; 1.40)
N = 1,253 | | 2^nd^ vs. 4^th^ (> 5–50 percentile) | 0.90 (0.50; 1.50)
| | 3^rd^ vs. 4^th^ (> 0–75 percentile) | 0.70 (0.40; 1.30)
Combined Incontinence in Men and Women
Nelson, 2005 ^4^ | 84 | Incremental increase by 1 unit in men and women in nursing homes | 0.98 (0.96; 1.00)
N = 8,170
FI
Melville, 2005 ^163^ | 30 – 90 | Obese women (BMI >29) vs. BMI<25 | 1.38 (0.99; 1.93)
N = 6,888 | | Overweight women (BMI 25–29) vs. BMI <25 | 0.95 (0.64; 1.40)
Chiarelli, 2003 ^658^ | 15–44 | >25 vs. <25 women 12 months postpartum | 0.82 (0.33; 2.02)
N = 568
Ballester, 2005 ^162^ | 20–64 | Women with BMI ≥25 vs. <25 | 2.30 (0.60; 8.30)
N = 103
MacArthur, 2001 ^214^ | 42.9 | 2nd quartile vs. lowest quartile in women 3 months postpartum | 0.79 (0.52; 1.21)
N = 7,879 | | 3rd quartile vs. lowest quartile in women 3 months postpartum | 1.00 (0.68; 1.47)
| | 4th quartile vs. lowest quartile in women 3 months postpartum | 0.72 (0.48; 1.09)
Abramov, 2005 ^226^ | 26–86 | ≥30 vs. 25 | 1.35 (0.72; 2.54)
N = 542 | | 25–30 vs. <25 | 1.28 (0.67; 2.44)
Nelson, 2005 ^4^ | 84 | Incremental increase by 1 unit in men and women in nursing homes | 0.98 (0.96; 1.00)
N = 8,170
Nelson, 1998 ^3^ | 84 | Incremental increase by 1 unit in men and women in nursing homes,1992 | 1.00 (1.00; 1.30)
N = 18,244 | | Incremental increase by 1 unit in men and women in nursing homes,1993 | 1.00 (1.00; 1.04)
Mazouni, 2005 ^689^ | 29.4 | Incremental increase by 1 unit in women13 months instrumental delivery | 1.00 (1.00; 1.00)
N = 159 | | Obese women | 1.20 (0.75; 1.92)
| | Obese women | 1.10 (0.70; 1.77)
| | Overweight women | 1.08 (0.65; 1.79)
| | Overweight women | 0.99 (0.60; 1.64)
Flatus Incontinence in Women
van Brummen, 2006 ^662^ | 30 | 23.7, 1 year postpartum | 1.00 (1.00; 1.00)
N = 487 | | 24.8, 1 year postpartum | 1.08 (1.02; 1.13)*
Abramov, 2005 ^226^ | 26–86 | ≥30 | 1.06 (0.65; 1.72)
N = 542 | | 25–30 | 1.40 (0.91; 2.16)
Uustal Fornell, 2004 ^185^ | >40 | Obese BMI >30 | 1.80 (1.00; 3.10)
N = 930 Obese | | Overweight >25 BMI | 1.70 (1.20; 2.40)*
1,304 Overweight
Liquid Feces Incontinence in Women
Uustal Fornell, 2004 ^185^ | >40 | Obese BMI >30 | 2.50 (1.40; 4.20)*
N = 930 Obese | | Overweight >25 BMI | 1.40 (0.90; 2.00)
1,304 Overweight
Solid Feces Incontinence in Women
Uustal Fornell, 2004 ^185^ | >40 | Obese BMI >30 | 1.30 (0.50; 3.80)
N = 930 Obese | | Overweight >25 BMI | 1.20 (0.60; 2.40)
1,304 Overweight
Diabetes Mellitus
AI in Women
Richter, 2005 ^208^ | 16–55 | Diabetes and morbid obesity before laparoscopic weight loss surgery | 0.59 (0.27; 1.31)
N = 180
Boreham, 2005 ^212^ | 18–64 | Diabetes | 1.54 (0.49; 4.80)
N = 457
Chen, 2003 ^213^ | ≥20 | Diabetes mellitus | 1.90 (0.90; 4.10)
N = 1,253
Combined Incontinence in Men and Women
Nelson, 2005 ^4^ | 84 | Diabetes, nursing homes, men and women | 1.00 (1.00; 1.00)
N = 8,170
Nakanishi, 1997 ^58^ | >65 | Men and women with diabetes | 0.26 (0.05; 1.23)
N = 1,405
FI
Quander, 2005 ^216^ | >65 | Men and women with diabetes | 1.70 (1.40; 2.10)*
N = 6,099
Ostbye, 2004 ^186^ | >65 | Prevalence in women with diabetes | 1.09 (0.63; 1.87)
N = 8,949 | | Incidence in women with diabetes | 1.30 (0.91; 1.87)
| | Prevalence in men with diabetes | 2.49 (1.32; 4.69)*
| | Incidence in men with diabetes | 1.32 (0.81; 2.15)
Nelson, 2005 ^4^ | 84 | Men and women with diabetes, nursing homes | 1.00 (1.00; 1.00)
N = 8,170
Nelson, 1998 ^3^ | 84 | Men and women with diabetes, nursing homes 1992 | 1.00 (1.00; 1.00)
N = 18,224 | | Men and women with diabetes, nursing homes 1993 | 1.00 (1.00; 1.00)
Nakanishi, 1997 ^58^ | >65 | Men and women with diabetes | 1.00 (0.47; 2.12)
N = 1,405 | | Men and women with diabetes | 3.08 (1.16; 8.17)*
Kalantar, 2002 ^217^ | >18 | Men and women with diabetes | 2.07 (0.68; 6.32)*
N = 642
Diet
Combined Incontinence
FI | | | 2.23 (1.24; 3.98)*
FI
Ostbye, 2004 ^186^ | >65 | Prevalence in women coffee drinker | 1.13 (0.78; 1.62)
N = 8,949 | | Incidence in women coffee drinker | 1.08 (0.82; 1.43)
| | Prevalence in men coffee drinker | 2.03 (1.05; 3.90)*
| | Incidence in men coffee drinker | 1.06 (0.70; 1.61)

Bold - multivariate odds ratios

* Significant difference

Inconsistent evidence suggested that men and women with diabetes had FI more frequently than nondiabetics with rates higher by 70 percent ^216^ to 300 percent ^58^ in older adults and by 207 percent in younger adults ^217^ after adjustment for other risk factors.

#### Physical activity

Physically active adults had a 70 percent lower risk of fecal urgency after adjustment for other risk factors (Appendix Table F37). ^125^ Distance runners had a FI prevalence of 12 percent in one study with no formal control comparison. ^663^ The association between physical activity and incidence of FI and quality of life related to FI in adults in community and LTC requires future investigation.

#### Smoking and pulmonary diseases

The association between smoking and FI is inconsistent in direction and effect size (Table 30). ^125,^ ^185,^ ^186,^ ^208,^ ^218,^ ^226,^ ^227^ White women with obstructive pulmonary diseases had a 208 percent higher rate of FI after adjustment for possible confounding factors. ^187^ Women with chronic bronchitis had liquid incontinence 3.5 times more often in a bivariate analysis. ^185^ Older men and women with protracted coughing experienced increased risk of combined UI and FI by 65 percent. ^114^

Table 30 Association between FI, smoking, and pulmonary diseases

Author | Age | Definition of Fecal Incontinence | Risk Factor in Population Groups | Odds Ratio (95% CI)
Sample
Smoking
Richter, 2005 ^208^ | 16–55 | AI | Current smoker women with morbid obesity before laparoscopic weight loss surgery | 0.58 (0.18; 1.84)
N = 180
Abramov, 2005 ^226^ | 26–86 | FI | Smoking women | 1.72 (0.79; 3.73)
N = 542
Ostbye, 2004 ^186^ | >65 | Incidence of FI | Women smoked <1 pack/day | 1.02 (0.75; 1.38)
N = 8,949 | | | Women smoked 1+ pack/day | 1.23 (0.83; 1.82)
| | | Men smoked <1 pack/day | 0.33 (0.17; 0.63)*
| | | Men smoked 1+ pack/day | 0.59 (0.32; 1.11)
| | | Women smoked <1 pack/day | 0.85 (0.56; 1.29)
| | | Women smoked 1+ packs/day | 1.33 (0.8; 2.2)
| | | Men smoked <1 pack/day | 0.42 (0.23; 0.78)*
| | | Men smoked 1+ pack/day | 0.67 (0.37; 1.2)
Bradley, 2005 ^125^ | Mean age of 68.2 | Fecal urgency | Smoking Women | 2.9 (0.7; 11.7)
N = 297
Guise, 2007 ^218^ | | Severity, incontinence of stool | Current smoking women | 1.85 (1.46; 2.35)*
N = 8,774
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Smoking men and women | 1 (0.7; 1.3)
N = 1,726
Abramov, 2005 ^226^ | 26–86 | Flatus incontinence | Smoking women | 0.95 (0.55; 1.62)
N = 542
Uustal Fornell, 2004 ^185^ | >40 | Flatus incontinence | Smoking women | 0.90 (0.60; 1.40)
N = 885 | >40 | Liquid feces incontinence | Smoking women | 0.70 (0.40; 1.10)
| | Solid feces incontinence | Smoking women | 0.60 (0.10; 0.80)*
Pulmonary Diseases
Richter, 2005 ^208^ | 16–55 | AI | Sleep apnea in women with morbid obesity before laparoscopic weight loss surgery | 1.46 (0.75; 2.82)
N = 180
Huang, 2006 ^187^ | | AI | Women with chronic obstructive pulmonary disease | 2.08 (1.18; 3.69)*
N = 345
Stenzelius, 2004 ^114^ | >75 | Combined incontinence | Men and women with protracted coughing | 1.65 (1.17; 2.32)*
N = 4,277
Uustal Fornell, 2004 ^185^ | >40 | Liquid incontinence | Women with chronic bronchitis | 3.50 (1.30; 9.90)*
N = 885 | | Solid incontinence | Women with chronic bronchitis | 2.20 (0.00; 13.30)

Bold - multivariate odds ratios

* Significant difference

#### Muscle-skeletal disorders

The crude prevalence of FI was 71 percent higher among older men with arthritis with attenuation of the association in multivariate analysis (Table 31). ^186^ Foot and ankle problems in elderly adults were associated with a two-fold increase in prevalence but not incidence of FI. ^186^ Arthritis in older men and women increased the risk of liquid FI by 80 percent in bivariate analysis of 1,352 adults over 75 years old. ^158^

Table 31 Association between FI and muscle-skeletal diseases

Author | Age | Fecal Incontinence | Risk Factors in Population Groups | Odds Ratio (95% CI)
Richter 2005 ^208^ | 16–55 | AI | Arthritis in women with morbid obesity before laparoscopic weight loss surgery | 1.64 (0.76; 3.55)
N = 180
Nelson, 2005 ^4^ | 84 | Combined incontinence | Arthritis in men and women in nursing homes | 0.80 (0.60; 1.00)
N = 8,170 | | FI | Arthritis in men and women in nursing homes | 0.80 (0.70; 1.00)
Nelson 1998 ^3^ | 84 | FI | Arthritis in men and women in nursing homes, 1992 | 0.90 (0.80; 1.00)
N = 18,224
Chiarelli, 2003 ^658^ | 15–44 | FI | Joint hyper mobility at 12 months postpartum | 2.75 (1.05; 7.19)
N = 568
Ostbye, 2004 ^186^ | >65 | Prevalence of FI | Arthritis in women | 1.43 (0.97; 2.1)
N = 8,949 | | Incidence of FI | Arthritis in women | 1.17 (0.86; 1.59)
| | Prevalence of FI | Arthritis in men | 1.29 (0.76; 2.81)
| | Incidence of FI | Arthritis in men | 0.96 (0.66; 1.39)
| | FI | Arthritis in men and women in nursing homes, 1993 | 0.80 (0.70; 0.90)*
| | Prevalence of FI | Foot and ankle trouble in women | 2.01 (1.18; 3.44)*
| | Incidence of FI | Foot and ankle trouble in women | 1.15 (0.79; 1.67)
| | Prevalence of FI | Foot or ankle trouble in men | 2.01 (1.18; 3.44)*
| | Incidence of FI | Foot or ankle trouble in men | 1.15 (0.79; 1.67)
Bliss, 2004 ^158^ | 75 | Severity, soils underwear or floor | Lower back pain/sciatica in men and women | 1.5 (1.1; 2.1)
N = 1,352 | | Type, liquid FI | Arthritis in men and women | 1.8 (1.2; 2.7)*

Bold - multivariate odds ratios

* Significant difference

#### Neoplasm

Older patients with rectal cancer had the highest prevalence of FI (55 percent), ^664^ but other studies showed lower prevalence of FI among patients with rectal cancer ^665,^ ^666^ (Appendix Table F38). Patients after proctocolectomy with J-pouch anastomosis reported 25 percent prevalence of FI with lower rates after W-pouch anastomosis. ^667^

#### Comorbidities

High rates of medical comorbidities in women were associated with a 2.6 times higher adjusted risk of FI (Table 32). ^163^ Incremental increases in the Charlson Comorbidity Scale scores in women were associated with 76 percent higher adjusted odds of FI. ^219^ The presence of kidney diseases in older adults was associated with a significant risk of incident FI by 48 percent in women and 94 percent in men. ^186^ Men suffering from transient ischemic attack had a three times higher prevalence of FI. ^219^ Women with arterial hypertension reported FI 2.4 times more often compared to normotensive females after adjustment for other risk factors. ^213^ Heart disease in nursing home residents did not increase the risk of FI. ^3,^ ^4^

Table 32 Association between FI and comorbidities

Author | Age | Definition of Fecal Incontinence | Risk Factors in Population Groups | Odds Ratio (95% CI)
Sample
Curless, 1994 ^702^ | 25–93 | FI | Colorectal cancer in men and women | 3.4 (1.5; 7.6)*
N = 31
Kalantar, 2002 ^217^ | >18 | FI | Radiation treatment to lower abdomen or pelvis in men and women | 2.72 (0.83; 8.89)
N = 642
Goode, 2005 ^219^ | | FI | Swelling in feet and legs in men | 3.49 (1.8; 6.76)*
N = 501 | | FI | transient ischemic attack/mini-stroke in men | 3.11 (1.3; 7.41)*
Nelson, 2005 ^4^ | 84 | Combined incontinence | Heart disease in men and women in nursing homes | 1.00 (1.00; 1.00)
N = 8,170 | | FI | Heart disease in men and women in nursing homes | 1.00 (1.00; 1.00)
Nelson, 1998 ^3^ | 84 | FI | Heart disease in men and women in nursing homes, 1992 | 0.90 (0.80; 1.00)
N = 18,224 | | FI | Heart disease in men and women in nursing homes, 1993 | 1.00 (1.00; 1.00)
Richter, 2005 ^208^ | 16–55 | AI | Hypertension in women with morbid obesity before laparoscopic weight loss surgery | 1.04 (0.55; 1.98)
N = 180
Chen, 2003 ^213^ | ≥ 20 | AI | Hypertension in women | 2.4 (1.2; 4.9)*
N = 1,253
Melville, 2005 ^163^ | 30 – 90 | FI | High medical comorbidity in women | 2.58 (1.66; 4.01)*
N = 6,888 | | FI | Moderate medical comorbidity in women | 1.76 (1.13; 2.73)*
Goode, 2005 ^219^ | | FI | Charlson Comorbidity Scale score in women | 1.29 (1.07; 1.55)*
N = 499
Ostbye, 2004 ^186^ | >65 | Prevalence of FI | Kidney diseases in women | 1.46 (0.95; 2.24)
N = 8,949 | | Incidence of FI | Kidney diseases in women | 1.48 (1.05; 2.09)*
| | Prevalence of FI | Kidney diseases in men | 1.70 (0.85; 3.87)
| | Incidence of FI | Kidney diseases in men | 1.94 (1.15; 3.27)*

Bold - multivariate odds ratios

* Significant difference

#### Stroke and other neurological disorders

The prevalence of FI was 30 percent ^221^ to 34 percent ^220^ after acute stroke (Appendix Table F39). The absolute risk of FI was less than 10 percent several months after stroke in most studies. ^220^ – ^222,^ ^668^ Stroke was associated with a significant increase in adjusted odds of FI in the majority of the studies (Table 33). Combined UI and FI was five times more frequent in community dwelling adults after stoke ^58^ but not in residents of nursing homes. ^4^ Incident FI occurred twice as frequently in women but not in men after a stroke. ^186^ Adjusted prevalence of FI was three ^216^ to five ^58^ times higher in stroke survivors compared to adults without a stroke. Incremental 10-year increase in age at the time of a stroke was associated with a 45 percent higher probability of FI 6 months after the stroke. ^220^ Diabetics experienced FI 2.2 times more often after stroke compared to non diabetics after adjustment for confounding factors. ^220^ Severity of stroke was positively associated with FI. ^220,^ ^221^ Functional dependency and need for assistance with toilet access 3 months after stroke in men and women was associated with a 349 percent increase in FI. Residents of nursing homes after stroke suffered from FI 1.2–1.3 times more often. ^4^ Adjustment for other risk factors of FI attenuated the strength of association, but a higher odds ratio was still highly significant (4.9, 95 percent CI 14; 16). ^58^

Table 33 Association between FI and stroke

Author | Age | Stroke in Population Groups | Odds Ratio (95% CI)
Sample
Combined Incontinence
Nelson, 2005 ^4^ | 84 | Men and women after stroke in nursing homes | 1.00 (1.00; 1.00)
N = 8,170
Nakanishi, 1997 ^58^ | >65 | Men and women after stroke | 5.39 (2.23; 13.05)*
N = 1,405
FI
Ostbye, 2004 ^186^ | >65 | Prevalence of FI in men after stroke | 1.44 (0.59; 3.53)
N = 8,949 | | Incidence of FI in men after stroke | 1.14 (0.64; 2.04)
| | Prevalence of FI in women after stroke | 1.54 (0.78; 3.07)
| | Incidence of FI in women after stroke | 2.07 (1.44; 2.98)*
Harari, 2003 ^221^ | | Dysphagia 7–10 days after stroke in men and women | 2.16 (1.2; 3.8)*
N = 1,069 | | Glasgow Coma Score ≥15 7–10 days after stroke in men and women | 1 (1; 1)
| | Glasgow Coma Score <15 7–10 days after stroke in men and women | 2.84 (1.6; 5)*
| | Initial UI 7–10 days after stroke in men and women | 17.96 (8.8; 36.8)*
Brittain, 2006 ^222^ | ≥40 | Men and women after stroke | 1.33 (1.01; 1.76)
N = 38,633
Harari, 2003 ^221^ | | Visual and/or sensory neglect 3 months after stroke in men and women | 0.98 (0.2; 5.3)
N = 846 | | Visual field defect 7–10 days after stroke in men and women | 2.69 (1.6; 4.6)*
N = 1,069
Nakayama, 1997 ^220^ | 75 | 10mm increase in lesion size 6 months after stroke in men and women | 1.30 (1.17; 1.47)*
N = 935 | | 10-year increase in age at stroke in men and women (FI was measured 6 months after stroke) | 1.45 (1.09; 1.93)*
| | Diabetes in men and women 6 month after stroke | 2.20 (1.14, 4.28)*
Harari, 2003 ^221^ | | Initial UI 3 months after stroke in men and women | 3.34 (0.6; 6.6)
N = 846 3 months after stroke | | Need for assistance with toilet access 3 months after stroke in men and women | 3.49 (1.4; 17.3)*
Nakayama, 1997 ^220^ | 75 | Other disabling diseases 6-month after stroke in men and women | 2.07 (1.07; 3.99)*
N = 935 | | Severity of stroke 6 months after stroke in men and women | 0.36 (0.29; 0.45)
Quander, 2005 ^216^ | >65 | Stroke in men and women | 2.80 (2.20; 3.50)*
N = 6,099
Nelson, 2005 ^4^ | 84 | Stroke in men and women in nursing homes (8,170) | 1.00 (1.00; 1.00)
N = 8,170 | | Stroke in men and women in nursing homes, 1992 (18,224) | 1.30 (1.20; 1.50)*
N = 18,224 | | Stroke in men and women in nursing homes, 1993 (18,224) | 1.20 (1.10; 1.30)*
Nakanishi, 1997 ^58^ | >65 | Stroke in men and women | 10.58 (5.81; 19.28)*
N = 1,405 | | Stroke in men and women | 4.85 (1.43; 16.41)*

Bold - multivariate odds ratios

* Significant difference

Several studies examined the prevalence of FI in patients with neurological diseases (Appendix Table F40). The prevalence of FI was 10 percent in men and 5 percent in women with Parkinson's Disease. ^669^ Two studies of patients with multiple sclerosis reported that 21 percent ^524^ to 51 percent ^670^ experienced FI. Among patients with spinal cord injury, subjects with tetraplegia had the highest prevalence of FI (14 percent) ^671^ compared to 4 percent in cases with paraplegia, and 2 percent in patients with incomplete injury. ^671^

#### Functional impairments and dependency status in association to FI in residents of nursing homes

were examined in one study using Wisconsin annual nursing home surveys (Table 34). ^3,^ ^4^ Tube feeding was associated with an 8–9 percent increase in the odds of FI, ^3^ dependence in daily activities with 6–7.3 higher odds of FI, and dependency in eating with four times higher odds of FI after adjustment for all risk factors in the model. ^3^ Nursing home institutionalization was examined in one study of 430 residents. ^166^ Increased length of stay from 2 weeks to 1 year was associated with a seven times higher prevalence of FI. ^166^ Residents with pressure ulcers experienced FI 2.3 to 2.6 times more often; this increase was independent of other FI risk factors. (Appendix Table F41) ^3^

Table 34 Association between FI and functional status of residents in nursing homes

Author | Risk Factors of Fecal Incontinence | Odds Ratio (95% CI)
Sample
Combined UI and FI
Nelson, 2005 ^4^ | Dementia | 1.80 (1.40; 2.20)*
N = 8,170 | Dependency in dressing | 2.00 (1.50; 2.70)*
| Dependency in eating | 1.60 (1.30; 2.10)*
| Dependency in hygiene | 1.60 (1.20; 2.20)*
| Impaired vision | 1.00 (1.00; 1.00)
| Trunk restraints | 2.90 (2.00; 4.30)*
| Tube feeding | 1.00 (1.00; 1.00)
| Depression | 1.00 (1.00; 1.00)
| Dementia | 1.70 (1.40; 2.00)*
Nelson, 1998 ^3^ | Dementia, 1992 | 1.50 (1.40; 1.70)*
N = 18,224 | Dementia, 1993 | 1.40 (1.30; 1.50)*
Nelson, 2005 ^4^ | Dependency in dressing | 1.90 (1.50; 2.50)*
N = 8,170 | Dependency in eating | 1.50 (1.20; 1.90)*
| Dependency in hygiene | 1.50 (1.10; 1.90)*
| Impaired vision | 1.00 (1.00; 1.00)
| Trunk restraints | 2.50 (1.70; 3.60)*
| Tube feeding | 1.00 (1.00; 1.00)
Nelson, 1998 ^3^ | Bed mobility, 1993 | 2.10 (1.90; 2.30)*
N = 18,224 | Dependency in dressing, 1992 | 1.00 (1.00; 1.00)
| Dependency in eating, 1992 | 4.10 (3.80; 4.40)*
| Dependency in hygiene, 1992 | 2.50 (2.00; 3.00)*
| Impaired vision, 1992 | 1.50 (1.40; 1.70)*
| Dependency in locomotion, 1992 | 1.10 (1.00; 1.20)
| Loss of activities of daily living, 1992 | 6.00 (4.70; 7.70)*
| Toilet use, 1992 | 5.20 (4.40; 6.10)*
| Transferring, 1992 | 1.00 (1.00; 1.00)
| Trunk restraints, 1992 | 3.20 (4.70; 7.70)*
| Tube feeding, 1992 | 7.60 (5.60; 10.40)*
| Bed mobility, 1993 | 2.20 (2.00; 2.40)*
| Dependency in dressing, 1993 | 1.50 (1.20; 1.90)*
| Dependency in eating, 1993 | 4.10 (3.80; 4.40)*
| Dependency in hygiene, 1993 | 2.20 (1.80; 2.70)*
| Impaired vision, 1993 | 1.40 (1.30; 1.50)*
| Dependency in locomotion, 1993 | 1.00 (1.00; 1.00)
| Loss of activities of daily living, 1993 | 7.30 (5.50; 9.70)*
| Toilet use, 1993 | 3.90 (3.30; 4.60)*
| Transferring, 1993 | 1.00 (1.00; 1.00)
| Trunk restraints, 1993 | 3.00 (2.70; 9.80)*
| Tube feeding, 1993 | 8.80 (6.30; 12.30)*
Nelson, 2005 ^4^ | Depression | 1.00 (1.00; 1.00)
N = 8,170
Nelson, 1998 ^3^ | Depression, 1992 | 1.00 (1.00; 1.00)
N = 18,224 | Depression, 1993 | 0.90 (0.80; 1.00)
Ouslander, 1993 ^166^ | 1 year vs. 2 months length of stay in nursing home | 5.194 (2.844; 9.483)*
N = 430 | 1 year vs. 2 weeks length of stay in nursing home | 7 (3.755; 13.048)*

Bold - multivariate odds ratios

* Significant difference

#### Functional status and mental health in association with FI in community dwelling adults

Poor general health and dementia increased the risk of combined UI and FI in adults after adjustment for confounding factors (Table 35). ^58^ Crude rates of combined incontinence were significantly higher in older adults with memory problems, edema in legs, and slow healing wounds. ^114^ The odds ratios of FI were significantly higher by 188 percent in women and by 218 percent in men with poor general health, ^219^ by 400 percent in adults with functional limitations, ^222^ and by 80 percent in adults with decreased mobility and severe/mild physical activity impairment. ^223^ Major depression in women was associated with 273 percent higher rates of FI independent of other risk factors. ^163^ Geriatric depression in men was associated with a 283 percent higher risk of FI. ^219^ Adults with dementia had FI twice as often in two studies after adjustment for other risk factors of FI. ^223,^ ^224^ Impaired cognitive status in men was associated with a five-fold increase in the adjusted odds ratio of FI. ^186^ Older men and women with Mini-Mental State Examination (MMSE) score <15 had a 250 percent increase in the adjusted rates of FI. ^223^

Table 35 Association between FI with functional status and mental health in adults

Author | Age | Risk Factors in Population Groups | Odds Ratio 95% CI
(Sample)
Combined UI and FI in Men and Women
Stenzelius, 2004 ^114^ | >75 | Definition of incontinence - difficulty talking | 2.13 (1.56; 2.93)*
(N = 4,277) | | Definition of incontinence - difficulty walking | 1.37 (0.98; 1.93)
| | Memory problems | 2.26 (1.48; 3.46)*
| | Mobility limitation | 1.40 (1.02; 1.92)
| | Edema in legs | 1.74 (1.30; 2.33)*
| | Slow-healing wounds | 1.94 (1.34; 2.81)*
Nakanishi, 1997 ^58^ | >65 | Anxiety | 1.13 (0.57; 2.23)
(N = 1,405) | | Dementia | 15.37 (3.77; 62.67)*
| | Poor general health | 9.44 (4.41; 20.19)*
| | Restricted social activity | 2.92 (0.96; 8.91)
| | Life not worth living | 1.65 (0.89; 3.03)
Endo, 2002 ^661^ (N = 605) | | Need help in instrumental activity of daily living | 0.821 (0.777; 0.867)
FI
Nakanishi, 1997 ^58^ | >65 | Anxiety | 1.32 (0.83; 2.1)
(N = 1,405) | | Anxiety | 1.1 (0.47; 2.58)
| | Dementia | 22.82 (9.22; 56.45)*
| | Dementia | 0.01 (0; 2.48)
Johanson, 1997 ^224^ (N = 388) | 31–103 | Dementia | 2.1 (1.6; 2.6)*
Chassagne, 1999 ^223^ | ≥60 | History of dementia | 2.1 (1.2; 3.5)
(N = 1,186) | | Mini-Mental Status Examination (MMSE) ≥15 | 1 (1; 1)
| | Mini-Mental Status Examination (MMSE) score <15 | 2.5 (1.4; 4.4)*
| | Neurological diseases | 1.9 (1; 3.4)
Ostbye, 2004 ^186^ (N = 8,949) | >65 | Cognitive status 3MS <78 in women | 1.8 (1.02; 3.2)
| | Cognitive status 3MS <78 in men | 1.28 (0.65; 2.54)
| | Cognitive status 3MS <50 in women | 2.55 (0.26; 25.27)
| | Cognitive status 3MS <50 in men | 6.29 (0.56; 71.2)
| | Cognitive status 3MS <78 in women | [underlined: 0.22 (0.05; 0.89)*]
| | Cognitive status 3MS <78 in men | [underlined: 1.03 (0.42; 2.52)]
| | Cognitive status 3MS <50 in women | [underlined: 1.04 (0.12; 8.75)]
| | Cognitive status 3MS <50 in men | [underlined: 4.57 (2.01; 10.35)*]
Stenzelius, 2004 ^114^ (N = 4,277) | >75 | Fatigue | 1.77 (1.13; 2.77)*
Goode, 2005 ^219^ (N = 501) | | Men living alone | 2.38 (1.23; 4.62)*
Chassagne 1999 ^223^ | ≥60 | Decreased mobility (severe/mild physical activity impairment) | 1.8 (1.1; 3)*
(N = 1,186)
Johanson 1997 ^224^ (N = 388) | 31–103 | Restricted mobility | 1.5 (1.2; 1.9)*
Nakanishi 1997 ^58^ | >65 | No life worth living | 1.74 (0.69; 4.39)
(N = 1,405) | >65 | No participation in social activity | 0.84 (0.34; 2.06)
| | Poor general health | 10.82 (6.8; 17.22)*
| | Poor general health | 2.34 (0.99; 5.53)
| | Social activity | 4.75 (2.68; 8.43)*
Brittain, 2006 ^222^ (N = 38,633) | ≥40 | Functional limitations | 4.02 (3.27; 4.95)*
Endo 2002 ^661^ (N = 533) | | Modifecal incontinence Cumulative Illness Rating Scale (CIRS) | 1.204 (1.056; 1.373)*
Kalantar 2002 ^217^ (N = 642) | >18 | Fair/poor general health | 2.74 (1.18; 6.36)*
Goode 2005 ^219^ | | Poor self-perceived health status in women | 1.88 (1.01; 3.5)*
(N = 501 men and 499 men) | | Poor self-perceived health status in men | 2.18 (1.13; 4.2)*
| | Geriatric depression scale score ≤5 in men | 1 (1; 1)
| | Geriatric depression scale score >5 in men | 2.83 (1.27; 6.28)*
Melville 2005 ^163^ (N = 6,888) | 30–90 | Major depression in women | 2.73 (1.67; 4.51)*

Bold - multivariate odds ratios;

italic - incidence of incontinence;

underlined - prevalence of fecal incontinence

* Significant difference

#### Chronic gastrointestinal conditions

Constipation, chronic diarrhea, and fecal impaction increased the adjusted relative odds of FI, but not combined incontinence, in residents of nursing homes (Appendix Table F42). ^3,^ ^4^ Constipation increased the risk of FI by 209–211 percent in women (Table 36). ^187,^ ^212^ Women with irritable bowel syndrome experienced FI 2.7 to 6.3 times more often after adjustment for other risk factors. ^187,^ ^211,^ ^212^ Crude rates of combined incontinence were significantly higher in men and women with chronic gastrointestinal disorders. ^114^ The adjusted rates of FI were 240 percent ^225^ to 450 percent ^219^ higher in women with diarrhea, 190 percent higher in irritable bowel syndrome patients, 250 percent higher in females with anal fistula, and 140 percent higher after cholecystectomy. ^225^ Adults with incomplete bowel evacuation had four times higher odds of FI. ^217^ Frequent diarrhea and water stools were associated with higher rates of liquid FI (Appendix Table F43). ^224^ One study reported increased crude rates of severe FI in association with chronic gastrointestinal problems in adults. ^158^

Table 36 Association between FI and gastrointestinal conditions in adults

Author | Age | Risk Factors in Population Groups | Odds Ratio (95% CI)
Sample
AI in women
Boreham, 2005 ^212^ | 18–64 | Constipation | 2.11 (1.22; 3.63)*
N = 457
Huang, 2006 ^187^ | | Frequent constipation | 2.09 (1.39; 3.16)*
N = 345
Boreham, 2005 ^212^ | 18–64 | Hemorrhoid surgery | 1.22 (0.36; 4.13)
N = 457
Meschia, 2002 ^211^ | 58.6 | Hemorrhoid surgery | 2.70 (1.10; 7.00)*
N = 881
Huang, 2006 ^187^ | | Irritable bowel syndrome, White women | 3.21 (2.1; 4.89)*
Meschia, 2002 ^211^ | 58.6 | Irritable bowel syndrome | 6.30 (3.50; 11.50)*
N = 881
Boreham, 2005 ^212^ | 18–64 | Irritable bowel syndrome | 3.22 (1.75; 5.93)*
N = 457
Combined UI and FI in Men and Women
Stenzelius, 2004 ^114^ | >75 | Constipation | 1.44 (1.06; 1.94)*
N = 4,277 | | Diarrhea | 7.72 (5.80; 10.29)*
| | Definition of incontinence difficulty swallowing | 1.63 (1.18; 2.26)*
FI in Women
Bharucha, 2006 ^225^ | ≥20 | Constipation | 1.1 (0.8; 1.5)
N = 2,800 | | Diarrhea | 2.4 (1.6; 3.6)*
| | Diarrhea ± constipation | 1.7 (0.98; 3)
| | Irritable bowel syndrome | 1.9 (1.3; 2.7)*
| | Urgency, no diarrhea or constipation | 5.1 (3.7; 7.1)*
| | Anal abscess | 1.1 (0.5; 2.4)
| | Anal fissure | 1.2 (0.9; 1.8)
| | Anal fistula | 2.5 (1.2; 5.2)*
| | Cholecystectomy | 1.4 (1.02; 1.9)*
Goode, 2005 ^219^ | | Chronic diarrhea | 4.55 (2.03; 10.2)*
N = 499 women and 501 men
Chiarelli, 2003 ^658^ | 15–44 | Constipation at twelve months postpartum | 2.46 (1.11; 5.46)*
N = 568
FI in Men and Women
Stenzelius, 2004 ^114^ | >75 | Abdominal pain | 1.86 (1.15; 3.01)*
N = 4,277 | | Diarrhea | 6.77 (4.20; 10.90)*
Kalantar, 2002 ^217^ | >18 | Hard or lumpy stool | 1.52 (0.8; 2.88)
N = 642 | | Incomplete evacuation | 3.72 (1.99; 6.96)*
| | Loose or watery stools | 4.89 (2.56; 9.33)*
| | Straining on defecation | 1.63 (0.85; 3.13)
| | Urgency | 5.57 (2.95; 10.51)*
Goode, 2005 ^219^ | | Chronic diarrhea in men | 6.08 (2.29; 16.16)*
N = 501 men
Johanson, 1997 ^224^ | 31–103 | Frequent diarrhea | 2.4 (1.3; 4.6)*
N = 388 | | Watery stool | 1.8 (1; 3)

Bold - multivariate odds ratios

* Significant difference

#### Surgical procedures

The majority of women (97 percent) after surgery for rectal prolapse experienced FI (Appendix Table F44). ^672^ Hemorrhoid surgery in women was associated with a 270 percent increase in the odds of FI. ^211^ Patients with inflammatory bowel disease after ileal pouch-anal anastomosis and pouchitis had a 43 percent prevalence of occasional and 11 percent of frequent FI. ^673^ Perianal surgery of the skin outside of the anal canal was associated with a five times higher adjusted odds ratio of FI. ^217^ The odds of FI were not significantly different among women after anorectal surgery after adjustment for parity and delivery. ^225^ Isolated flatus incontinence at least once a week occurred 1.5 times more often after previous lower abdominal or urological surgery. ^227^ The association was not consistent across different surgeries and studies. Gynecological surgery increased the adjusted odds ratio of AI by 180 percent (Appendix Table F45). ^213^

#### Drug administration

Crude rates of combined UI and FI were higher after diuretic and laxative use (Appendix Table F46). ^661^ One large study of 6,099 adults over 65 years old reported a significant increase in the adjusted odds of FI after anticonvulsants, antidepressants, anti Parkinson medications, antipsychotic, narcotics, and hypnotics. ^216^ Hormone replacement therapy in morbidly obese women before laparoscopic weight loss surgery ^208^ and contraceptive use ^225^ did not show a significant association with FI.

#### Prostate diseases

The prevalence of FI was less than 10 percent in all studies among men with prostate diseases (Appendix Table F47). ^180,^ ^674,^ ^675^ Prostate diseases, including prostate cancer, were associated with an increased adjusted odds ratio of FI (Table 37). ^180,^ ^219^ Both baseline prostate diseases and treatments have been associated with an increased risk of FI. Baseline FI before perineal prostatectomy for localized prostate cancer was associated with 600 percent higher adjusted rates of FI and 400 percent higher rates of severe FI after surgery. ^676^ Patients with positive surgical margins experienced severe FI seven times more often after surgery. ^676^ Radical prostatectomy was associated with a significant increase in the adjusted odds ratio of FI by 530 percent compared to healthy controls. ^180^ External beam radiation was associated with higher rates of bowel symptoms than radical prostatectomy independent of other confounding factors. ^677,^ ^678^

Table 37 Association between FI and prostate diseases

Author | Age | Incontinence and Bowel Symptoms | Risk Factors | Odds Ratio (95% CI)
Sample
Adolfsson, 1998 ^180^ | 50–80 | FI | Not reporting any treatment for prostate diseases | 2.20 (0.40; 11.00)
N = 359
Goode, 2005 ^219^ | | FI | Prostate diseases | 2.29 (1.04; 5.02)*
N = 501
Adolfsson, 1998 ^180^ | 50–80 | FI | Treatment for prostate cancer; endocrine | 3.20 (0.80; 12.10)
N = 359 | | | Treatment for prostate cancer; endocrine treatment subsequent to external radiation or radical prostatectomy | 1.80 (0.30; 12.40)
| | | Treatment for prostate cancer; external radiation | 3.80 (0.90; 15.90)
| | | Treatment for prostate cancer; prostatectomy | 5.30 (1.40; 20.20)*
| | | Prostate cancer | 3.10 (1.30; 8.00)*
Kirschner-Hermanns, 2005 ^676^ | 63.4 | FI | Baseline fecal incontinence before extrafascial perineal prostatectomy for Stage cT1–cT3N0M0 prostate cancer | 6.02 (2.29; 15.80)*
N = 132 | | | Prostate volume before extrafascial perineal prostatectomy for Stage cT1–cT3N0M0 prostate cancer | 1.02 (1.00; 1.05)
| | Severe FI | Baseline FI before extrafascial perineal prostatectomy for Stage cT1–cT3N0M0 prostate cancer | 3.96 (1.27; 12.39)*
| | | Positive surgical margins after extrafascial perineal prostatectomy for Stage cT1–cT3N0M0 prostate cancer | 7.22 (2.05; 25.44)*
Potosky, 2004 ^678^ | 55–82 | Bleeding with bowel movements | 5 years radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.58 (0.31; 1.06)
N = 1,187 | | Bothered by frequent bowel movement to pain, or urgency | 5 years radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 1.23 (0.52; 2.89)
Potosky, 2000 ^677^ | 55–79 | Bothered by frequent bowel movement, pain, or urgency | 2 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.68 (0.31; 1.50)
N = 1,591
Adolfsson, 1998 ^180^ | 50–80 | Bowel urgency | Not reporting any treatment for prostate disease | 1.00 (0.40; 2.40)
Potosky, 2000 ^677^ | 55–76 | Bowel urgency | 2 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.40 (0.27; 0.59)*
N = 1,591
Potosky, 2004 ^678^ | 55–76 | Bowel urgency | 5 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.56 (0.36; 0.87)*
N = 1,187
Adolfsson, 1998 ^180^ | 50–80 | Bowel urgency | Treatment for prostate cancer: endocrine | 1.30 (0.50; 3.30)
N = 359 | | | Treatment for prostate cancer: endocrine treatment subsequent to external radiation or radical prostatectomy | 2.50 (0.90; 6.90)
| | | Treatment for prostate cancer: external radiation | 2.40 (0.90; 6.20)
| | | Treatment for prostate cancer: prostatectomy | 0.90 (0.10; 6.00)
| | | Prostate cancer | 1.50 (0.80; 2.70)
| | | No prostate cancer | 1.00 (1.00; 1.00)
| | Constipation | Not reporting any treatment | 1.70 (0.70; 4.20)
| | | Treatment for prostate cancer: endocrine | 1.00 (0.30; 3.60)
| | | Treatment for prostate cancer: endocrine treatment subsequent to external radiation or radical prostatectomy | 3.90 (1.40; 10.40)*
| | | Treatment for prostate cancer: external radiation | 2.00 (0.60; 6.90)
| | | Treatment for prostate cancer: prostatectomy | 2.20 (0.50; 9.40)
| | | With prostate cancer | 1.80 (0.90; 3.80)
| | | Without prostate cancer | 1.00 (1.00; 1.00)
Potosky, 2004 ^678^ | 55–74 | Diarrhea | 5 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.84 (0.55; 1.26)
N = 1,187 | | | 5 years radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.70 (0.41; 1.22)
Potosky, 2000 ^677^ | 55–74 | Diarrhea | 2 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.50 (0.34; 0.72)*
N = 1,591 | | Painful bowel movements | 2 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 1.00 (0.58; 1.80)
Potosky, 2004 ^678^ | 55–75 | Painful bowel movements | 5 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 1.31 (0.73; 2.35)
N = 1,187
Potosky, 2000 ^677^ | 55–78 | Painful hemorrhoids | 2 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.38 (0.23; 0.64)*
1,591N =
Potosky, 2004 ^678^ | 55–78 | Painful hemorrhoids | 5 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.43 (0.25; 0.74)*
N = 1,187 | | Passing mucus from rectum | 5 years radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.36 (0.20; 0.66)*
| | Tenderness during bowel movements | 5 years radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.85 (0.46; 1.56)
Potosky, 2000 ^677^ | 55–77 | Wetness in rectal area | 2 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.63 (0.40; 0.99)*
N = 1,1591
Potosky, 2004 ^678^ | 55–77 | Wetness in rectal area | 5 years after radical prostatectomy vs. external beam radiotherapy for localized prostate cancer | 0.75 (0.47; 1.20)
N = 1187

Bold - multivariate odds ratios

* Significant difference

#### Anal trauma

Consistent evidence suggests that anal trauma was associated with significant risk of FI independent of other risk factors (Table 38). The adjusted odds of FI were 4.4 times higher in women with anal sphincter tear. ^232^ Women with anal injury not related to childbirth had 240 percent increases in FI. ^225^ The adjusted odds ratio of bothersome FI was 16 times higher in women with anal sphincter defect. ^679^ A combination of anal injury and pelvic organ prolapse increased the odds of bothersome FI by seven times. Women with anal injury, pelvic organ prolapse, and UI had an adjusted odds ratio of 55 to experience bothersome FI. ^679^ Perianal injury increased risk of FI by 262 percent in men and women in one study. ^217^ The independent contribution of anal injuries in males and females by age and race categories requires future investigation. Abortions were not associated with FI in one study (Appendix Table F48). ^227^ Menopause did not increase the adjusted odds of FI ^210,^ ^213^ but was associated with a higher prevalence of FI in another study ^226^ (Appendix Table F49).

Table 38 Association between FI and anal trauma in females

Author | Age | Definition of Incontinence | Risk Factor | Odds Ratio (95% CI)
Sample
Faltin, 2001 ^232^ | 15–93 | AI | Anal sphincter tear in women | 4.4 (2; 9.1)*
N = 1,228
Kalantar,2002 ^217^ | >18 | FI | Perianal injury in men and women | 2.62 (1.11; 6.23)*
N = 642
Bharucha, 2006 ^225^ | ≥20 | FI | Non childbirth anal injury in women | 2.4 (1.3; 4.5)*
N = 2,800
Faltin, 2006 ^695^ | | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | Anal sphincter tear 18 years after rupture of anal sphincter during childbirth | 1.7 (1; 2.8)
N = 540
Nichols, 2005 ^679^ | 53 | Bothersome AI | Anal sphincter defect in women | 16.10 (6.80; 38.20)*
N = 190 | | | Anal sphincter defect on ultrasonography and pelvic floor disorders vs. no defect in women | 36.40 (12.00; 114.00)*
| | | Anal sphincter defect on ultrasonography and pelvic floor disorders vs. no defect in women | 5.90 (3.00; 11.00)
| | | Anal sphincter injury in stage 0 or I pelvic organ prolapse and no UI in women | 7.20 (1.80; 28.10)*
| | | Anal sphincter injury in stage II pelvic organ prolapse and/or UI in women | 55.00 (13.00; 230.00)*

Bold - multivariate odds ratios

* Significant difference

#### FI in association with UI

The prevalence of FI was 25 percent ^210^ to 28 percent ^680^ in women with stress UI and 41 percent in women with overactive bladder. ^210^ UI was associated with 11–12 times higher odds of FI in residents of nursing homes in one study (Appendix Table F50). ^3^ Several studies reported an increase in the crude odds of FI in patients with UI ^187,^ ^208,^ ^210^ – ^213,^ ^681^ but only one study ^211^ found a significant (1.9 times) increase in the adjusted odds ratio of FI in 881 women with UI (Table 39). Urinary symptoms other than UI in men and women were associated with a significant increase in crude odds of combined UI and FI in one study. ^114^ UI in men and women was associated with 2.9 ^223^ to eight times greater odds of FI. ^222^ The adjusted odds of FI in women with UI were two to six times higher compared to continent females. ^162,^ ^163,^ ^219,^ ^226^ The presence of stage II pelvic organ prolapse and/or urinary incontinence compared to stage 0 or I pelvic organ prolapse and no UI increased the adjusted odds of bothersome FI by 4.9 times. ^679^

Table 39 Association between FI and UI

Author | Age | Risk Factors | Odds Ratio (95% CI)
Sample
AI
Boreham, 2005 ^212^ | 18–64 | UI | 2.66 (1.65; 4.28)*
N = 457
Meschia, 2002 ^211^ | 58.6 | Detrusor instability | 2.30 (1.20; 4.10)*
N = 881
Ng, 2002 ^210^ | | Genuine stress incontinence | 1.19 (0.42; 3.40)
N = 320
Meschia, 2002 ^211^ | 58.6 | Genuine stress incontinence | 1.60 (1.10; 2.30)*
N = 881
Ng, 2002 ^210^ | | Mixed incontinence | 1.80 (0.56; 5.77)
N = 320
Meschia, 2002 ^211^ | 58.6 | Mixed incontinence | 2.30 (1.30; 3.90)*
N = 881
Ng, 2002 ^210^ | | Overactive bladder | 1.10 (0.42; 2.88)
N = 320
Chen, 2003 ^213^ | ≥20 | Overactive bladder | 3.2 (1.6; 6.7)*
N = 1,253
Nichols, 2004 ^681^ | 57 | Pelvic organ prolapse and urinary incontinence vs. UI only or pelvic organ prolapse only | 2.72 (1.20; 6.10)*
N = 100
Chen, 2003 ^213^ | ≥20 | Stress UI | 1.5 (0.7; 3)
N = 1,253
Richter, 2005 ^208^ | 16–55 | UI in women with morbid obesity before laparoscopic weight loss surgery | 6.34 (2.52; 15.93)*
N = 180
Meschia, 2002 ^211^ | 58.6 | UI | 1.90 (1.30; 2.80)*
N = 881
Huang, 2006 ^187^ | | UI, Asian women | 2.22 (1.32; 3.76)*
N = 345 | | UI, White women | 3.38 (2.52; 4.53)*
Combined UI
Stenzelius, 2004 ^114^ | >75 | Urinary symptoms other than UI in men and women | 2.29 (1.69; 3.12)*
N = 4,277
FI
Chiarelli, 2003 ^658^ | 15–44 | UI 1 year postpartum | 0.83 (0.04; 17.05)
N = 568 | | Flow-stopping inability 1 year postpartum | 1.22 (0.5; 2.92)
| | UI 1 year postpartum | 0.26 (0.02; 2.53)
Brittain, 2006 ^222^ | ≥40 | UI in men and women | 8.1 (6.62; 9.69)*
N = 38,633
Chiarelli, 2003 ^658^ | 15–44 | UI 12 months postpartum | 6.03 (2.37; 15.33)*
N = 568 | | UI before pregnancy | 1.6 (0.58; 4.4)
| | UI during pregnancy | 0.66 (0.27; 1.61)
Chassagne, 1999 ^223^ | ≥60 | History of UI in men and women | 2.9 (1.8; 4.6)*
N = 1,186
Abramov, 2005 ^226^ | 26–86 | Stress UI | 2.11 (1.12; 3.98)*
N = 542
Melville, 2005 ^163^ | 30–90 | UI | 2.32 (1.7; 3.15)*
N = 6,888
Ballester, 2005 ^162^ 2 | 20–64 | UI | 6 (1.7; 21)*
N = 103
Goode, 2005 ^219^ | | UI | 2.65 (1.34; 5.25)*
N = 499
Flatus Incontinence
Kjolhede, 2005 ^683^ | | Burch colposuspension for UI vs. healthy controls 14 years after surgery | 1.98 (1.17; 3.37)*
N = 508
Abramov, 2005 ^226^ | 26–86 | Stress UI | 1.72 (1.14; 2.59)*
N = 542
Uustal Fornell, 2004 ^185^ | >40 | UI | 4.80 (3.00; 7.80)*
N = 885
Liquid Feces Incontinence
Bliss ^158^ | Mean age of 75±6 | UI in men and women | 2.9 (1.9; 4.2)*
N = 1,352
Kjolhede, 2005 ^683^ | | Burch colposuspension for UI vs. healthy controls 14 years after surgery | 3.67 (1.43; 9.42)*
N = 508
Uustal Fornell, 2004 ^185^ | >40 | UI | 4.90 (2.90; 8.70)*
N = 885
Mucus Incontinence
Bliss, 2004 ^158^ | Mean age of 75±6 | UI in men and women | 3.6 (1.2; 12)*
N = 1,352
Solid Feces Incontinence
Kjolhede, 2005 ^683^ | | Burch colposuspension for UI vs. healthy controls 14 years after surgery | 2.96 (0.42; 20.90)
N = 508
Uustal Fornell, 2004 ^185^ | >40 | UI | 5.90 (2.40; 14.60)*
N = 885

Bold - multivariate odds ratios

* Significant difference

#### Prolapse

Most studies reported a prevalence of FI of more than 10 percent in women with genital prolapse (Appendix Table F51). The adjusted odds of FI were 1.9 times in patients with rectal prolapse ^211^ and 3.2 ^213^ to five times in women with utero-vaginal prolapse (Appendix Table F52). One study reported a significant increase in the crude odds of flatus, liquid, and solid FI in women with genital prolapse. ^185^ More than a third of men and women with rectal prolapse reported FI. ^682^ Burch colposuspension was associated with greater adjusted odds of flatus and liquid FI compared to healthy controls 14 years after surgery. ^683^ Women after Burch colposuspension also experienced more severe flatus and liquid incontinence with greater impact on their quality of life (Appendix Table F53). ^683^

#### FI related to pregnancy and birth

Consistent evidence suggested a significant dose response increase in the absolute risk of FI after vaginal trauma. The prevalence of FI was 7 percent at 3 months and 5 percent at 12 months postpartum (Appendix Table F54). ^684^ Women with sphincter tears experienced higher rates of FI, from 15 percent among nullipara to 30 percent after more than two deliveries. ^685^ The highest prevalence (40 percent) was reported in nullipara with fourth degree sphincter tear after index delivery. ^686^ Less than 1 percent of women experienced FI after vacuum delivery. ^211^ The prevalence was 2 percent ^211^ to 5 percent ^687^ after forceps delivery and 13 percent ^211^ after episiotomy or vaginal delivery. ^210^ The prevalence of combined UI and FI was 6 percent at 10 months ^688^ and 2 percent at 24 months postpartum. ^684^ Pregnant women ^657^ and women after episiotomy ^628^ reported 13 percent FI. The prevalence of FI was lower by 1 percent in nulliparous and 3 percent after spontaneous vaginal delivery. ^163^ The prevalence of FI was lowest (0.3 percent) after Cesarean sections. ^163^ The prevalence of flatus was 4 percent in pregnant women with one previous delivery, ^227^ 6 percent at 3 months after delivery, ^684^ 8 percent after instrumental delivery, ^689^ and 25 percent after previous multiple pregnancies ^689^ and among multiparous women. ^658^ One small study reported the highest prevalence of flatus 30 years postpartum in women with anal disruption (59 to 76 percent) and episiotomy (70 percent). ^690^ The prevalence of liquid incontinence was less than 6 percent ^227,^ ^658^ and solid incontinence less than 5 percent ^227,^ ^658,^ ^684,^ ^688^ in pregnant women and after different modes of delivery. Women with obstetric sphincter tears experienced higher rates of incident FI and severe FI (Appendix Table F55). More than 5 percent of women with complete third-degree tears after the first pregnancy and more than two deliveries after that experienced severe FI. ^685^ Almost 7 percent of women 12 months after instrumental delivery and/or a high birth weight infant reported solid and liquid FI. ^658^ Complete FI with liquid and solid incontinence was reported by 12 percent of women 13 years after an obstetrical anal sphincter tear. ^691^ More than 2 percent of young women 3 months postpartum complained about weekly solid or liquid incontinence. ^228^

The relative effects of different risk factors were less consistent across the studies and depended on the definitions of FI and adjustment for confounding factors (Table 40). The adjusted odds of FI were significantly increased after delivery of heavy babies, ^202^ among women with narrow subpubic arch angle, ^692^ and with FI during pregnancy, ^209^ after increased number of births, ^215,^ ^226^ and a high degree of perineal injury. ^187,^ ^209,^ ^228^ – ^231^ No independent significant risk factors were reported for solid FI. ^185,^ ^693,^ ^694^ Caesarean section was associated with a reduced risk of frequent FI ^214^ in contrast with forceps delivery followed by frequent and persistent FI ^214,^ ^215,^ ^218^ (Table 41). The number of births ^215^ and anal injury ^218,^ ^227^ were associated with higher adjusted odds of severe FI.

Table 40 Association between FI and pregnancy related risk factors

Author | Age | Risk Factors | Time from Exposure to Outcome | Odds Ratio (95% CI)
Sample
AI
Casey, 2005 ^202^ | | 3^rd^ or 4^th^ degree laceration vs. no laceration | Within 7 months of delivery, at or before their 6-month contraceptive followup after delivery | 1 (0.5; 2)
N = 3,887 | | Birth weight >4,000g vs. <4,000g | | 2.4 (1.3; 4.4)*
| | Cesarean delivery vs. vaginal | | 0.6 (0.2; 2)
| | Epidural analgesia vs. no analgesia | | 1.2 (0.7; 1.9)
| | Episiotomy vs. no episiotomy | | 1 (0.4; 2.3)
| | Forceps delivery vs. vaginal | | 1.2 (0.5; 2.9)
| | Oxytocin augmentation vs. no oxytocin augmentation | | 0.7 9 (0.3; 1.6)
| | Second stage >2 hours vs. <2 hours | | 0.4 (0.2; 1.1)
Frudinger, 2002 ^692^ | 22–39 | Birth weight of baby (increment - 1kg) | | 1.31 (0.34; 4.99)
N = 134 | | Head circumference of baby (increment cm) | | 1.11 (0.74; 1.67)
| | Narrow subpubic arch angle vs. normal | | 8.69 (3.15; 23.94)*
| | Caesarean delivery vs. vaginal | | 0.31 (0.06; 1.62)
| | Forceps delivery vs. no forceps | | 1.36 (0.35; 5.29)
| | Second stage (hours) | | 0.89 (0.57; 1.39)
| | Ultrasonic evidence of injury, perineal scar vs. no scar | | 2.69 (0.7; 10.33)
| | Ultrasonic evidence of injury, sphincter scar vs. no injury | | 2.26 (0.69; 7.36)
Eason, 2002 ^228^ | | Episiotomy without extension into anal sphincter perineal injury vs. no episiotomy | 3 months postpartum | 1.3 (0.9; 1.8)
N = 252 | | FI - degree tear perineal injury vs. no perineal injury | | 1.2 (0.8; 1.7)
| | Forceps delivery vs. vaginal | | 1.4 (1; 2.1)
| | 3rd or 4th-degree tear perineal injury vs. no injury | | 2.1 (1.4; 3.1)*
| | Vacuum delivery vs. vaginal | | 1.3 (0.9; 1.8)
| | % of days perineal massage performed ≥67 days vs. <33 days | | 0.8 (0.6; 1.1)
| | % of days perineal massage performed 33–66 days vs. <33 days | | 1 (0.8; 1.3)
| | Episiotomy vs. no episiotomy | | 1.1 (0.8; 1.4)
| | Infant birth weight, ≥4,000g vs. <4,000g | | 1.2 (0.9; 1.6)
| | Length of second stage of labor, ≥1.5 hour (vaginal delivery only) vs. <0.5 hour | | 0.9 (0.7; 1.2)
| | Length of second stage of labor, 0.5–0.9 hour (vaginal delivery only) vs. <0.5 hour | | 0.8 (0.6; 1.2)
| | Length of second stage of labor, 1–1.4 hour (vaginal delivery only) vs. <0.5 hour | | 0.8 (0.6; 1.2)
Faltin, 2001 ^696^ | 15–93 | External and internal anal sphincter defect vs. no defect | 3 months after delivery | 7.4 (1.7; 31.4)*
N = 100 | | | 30 months after delivery | 5.3 (1.2; 24.1)*
| | Isolated external anal sphincter defect vs. no defect | 3 months after delivery | 6.2 (1.2; 32)
| | | 30 months after delivery | 6.5 (1.3; 33.4)
| | Isolated internal anal sphincter defect | 3 months after delivery | 1.9 (0.2; 18.7)
| | Anal sphincter tear (clinically diagnosed) vs. no tear | 3 months after delivery | 4.3 (1.9; 9.7)*
| | | 30 months after delivery | 3.4 (1.2; 9.8)*
| | Baby weight >4,000g vs. <4,000g | | 0.7 (0.4; 1.4)
| | Clinically occult anal sphincter tears vs. no tears | 3 months after delivery | 3.8 (0.8; 17.1)
| | | 30 months after delivery | 7.7 (1; 60.1)
| | No subsequent delivery vs. delivery again | | 2.8 (1; 8.3)
| | Operative delivery vs. no operative delivery | | 1.6 (0.9; 2.7)
| | Parity vs. nulliparity | | 3.1 (1.6; 6)*
| | Sphincter defects diagnosed after endosonography 3 months after delivery vs. no defect | Transient shortly after delivery | 2 (1.4; 2.8)*
| | | 3 months after delivery | 1.9 (1.4; 2.6)*
| | | 30 months after delivery | 1.9 (1.3; 2.8)*
Boreham, 2005 ^212^ | 18–64 | Nulliparity vs. parity | | 0.63 (0.4; 0.99)
N = 457 | | Vaginal parity (per delivery) | | 1.16 (1; 1.35)
Zetterstrom, 1999 ^703^ | 30 | 10 years increase in maternal age | 9 months postpartum | 3.00 (1.40; 6.40)*
N = 349 | | Sphincter tear vs. no tear | | 2.40 (1.04; 4.90)*
Pollack, 2004 ^209^ | 30 | AI at 5 months vs. anal continence | Five years after first vaginal delivery | 3.80 (2.00; 7.30)*
N = 349 | | AI at 9 months vs. anal continence | | 4.30 (2.20; 8.20)*
| | Sphincter tear vs. no tear | | 2.30 (1.10; 5.00)*
| | Subsequent childbirth | | 2.40 (1.10; 5.60)*
Pregazzi, 2002 ^704^ | 2,143 | Anal sphincter and rectal mucosa tears vs. intact perineum and superficial tears | Immediately after vaginal delivery | 8.78 (2.60; 134.10)*
N = 218 | | Perineal muscle tears vs. intact perineum and superficial tears | | 1.48 (0.10; 14.60)
Lal, 2003 ^698^ | 28 | Cesarean delivery vs. spontaneous vaginal delivery | 10 months postpartum | 0.61 (0.25; 1.53)
N = 184 | | Cesarean delivery with labor vs. vaginal delivery | | 1.66 (0.83; 3.32)
| | Cesarean delivery without labor vs. vaginal delivery | | 1.62 (0.81; 3.23)
Huang, 2006 ^187^ | | History of 3^rd^ or 4^th^ degree vaginal tear vs. no tear, Asian American women | | 2.41 (1.14; 5.1)*
Richter, 2005 ^208^ | 16–55 | Number of Cesarean deliveries | Morbid obesity before laparoscopic weight loss surgery | 0.84 (0.55; 1.29)
N = 180 | | Number of children | | 1.11 (0.86; 1.44)
| | Number of vaginal deliveries | | 1.18 (0.92; 1.53)
Nichols, 2004 ^681^ | 57 | Operative vaginal delivery vs. no operative | | 3.75
N = 100 | | | | (1.60; 8.70)*
Chen, 2003 ^213^ | ≥20 | Parity ≥1 vs. nulliparity | | 3.4 (1.2; 9.5)*
N = 1,253
Peschers, 2003 ^694^ | 34 | Vacuum vs. spontaneous vaginal delivery | 6–24 weeks postpartum | 0.83 (0.36; 1.93)
N = 100
Ng, 2002 ^210^ | | Vaginal delivery vs. no vaginal delivery | | 1.09 (0.34; 1.25)
N = 320
FI
McKinnie, 2005 ^657^ | 42.7 | >1 pregnancy vs. no term pregnancy | | 2.26
N = 1,004 | | | | (1.22; 4.19)*
| | >1 pregnancy and >1 vaginal delivery vs. no vaginal delivery | | 2.15 (0.97; 4.77)
| | >1 pregnancy and >1 vaginal delivery vs.>1 pregnancy, no vaginal delivery | | 1.93 (0.81; 4.60)
| | >1 pregnancy and >1 vaginal delivery vs. no term pregnancy | | 2.41
| | | | (1.30; 4.49)*
| | >1 pregnancy and vaginal delivery vs. no term pregnancy | | 1.13 (0.43; 2.96)
| | >1 pregnancy vs. no term pregnancy | | 1.35 (0.69; 5.74)
De Leeuw, 2001 ^229^ | | Extent of perineal damage (per grade: grade-IV vs. grade-IIIb vs. grade-IIIa) | After anal sphincter damage during delivery | 2.54 (1.45; 4.45)*
N = 250 | | Mediolateral episiotomy, primiparity vs. no episiotomy | | 0.17 (0.05; 0.61)
| | Primiparity, without episiotomy | | 1.16 (0.41; 3.29)
| | Subsequent vaginal delivery | | 2.32 (0.85; 6.33)
| | Mediolateral episiotomy, multiparity | | 1.25 (0.27; 5.83)
| | Primiparity, with episiotomy | | 0.15
| | | | (0.02; 0.98)*
Chiarelli, 2003 ^658^ | 15–44 | Instrumental delivery vs. no instrumental delivery | At 12 months postpartum | 0.83 (0.31; 2.2)
N = 568 | | Marked abdominal striae | | 2.34 (0.91; 6.02)
| | Multiparity vs. nulliparity | | 1.42 (0.53; 3.83)
| | Perineal trauma (tear with sutures and/or episiotomy) | | 1.67 (0.67; 4.14)
Melville, 2005 ^163^ | 30 – 90 | Cesarean deliveries only | | 0.87 (0.42; 1.8)
N = 6,888 | | History of operative vaginal delivery vs. no history | | 1.52
| | | | (1.09; 2.12)*
| | Mixed/unknown delivery types vs. vaginal | | 1.44 (0.82; 2.54)
| | Nulliparity | | 1.35 (0.88; 2.08)
Signorello, 2000 ^697^ | | 2nd/3rd/4th degree tear vs. intact/1st degree tear | 3 months postpartum | 1.40 (0.40; 5.00)
N = 626 | | | 6 months postpartum | 1.20 (0.20; 6.40)
van Brummen, 2006 ^662^ | 30 | 3rd/4th degree tear vs. no tear | 1 year after delivery | 6.82
N = 487 | | | | (4.20; 11.00)*
Mazouni, 2005 ^689^ | 29.4 | Age (years) | 12 months instrumental delivery | 1.00 (1.00; 1.00)
N = 159 | | Birth weight (g) | 18 months instrumental delivery | 1.00 (1.00; 1.00)
| | Episiotomy vs. no episiotomy | 16 months instrumental delivery | 1.00 (1.00; 1.00)
| | Length of labor | 15 months instrumental delivery | 1.00 (1.00; 1.00)
| | 3rd-degree tears | 17 months instrumental delivery | 1.00 (1.00; 1.00)
Sultan, 1993 ^705^ | 18–43 | Any anal-sphincter defect after vaginal delivery vs. no defect | | 2.70
N = 124 | | | | (1.97; 3.71)*
Sultan, 1993 ^699^ | | Forceps delivery | | 1.81 (0.12; 27.72)
N = 90
Abramov, 2005 ^226^ | 26–86 | At least 1 episiotomy | | 1.03 (0.45; 2.32)
N = 274 | | At least 1 forceps delivery | | 0.98 (0.4; 2.41)
| | At least 1 prolonged second stage of labor (>2 hrs) | | 1.12 (0.49; 2.54)
| | At least 1 birth weight >4,000g | | 1.19 (0.56; 2.53)
Abramov, 2005 ^226^ | 26–86 | Cesarean only | | 0.39 (0.13; 1.04)
N = 346
Abramov, 2005 ^226^ | 26–86 | Parity ≥2 | | 3.09
N = 542 | | | | (1.25; 7.65)*
| | Parity, 1 | | 1.32 (1; 2.3)
van Brummen, 2006 ^662^ | 30 | Birth weight g 3107 vs. >3,445 | 1 year after delivery | 0.99 (0.99; 1.01)
N = 487 | | FI at 12 weeks gestation | | 2.60
| | | | (0.90; 12.10)
MacArthur, 2001 ^214^ | 42.9 | Breech delivery vs. vaginal | 3 months postpartum | 1.49 (0.42; 5.24)
N = 7,879 | | Caesarean section vs. vaginal | | 0.58 (0.35; 0.97)
| | Forceps delivery | | 1.94
| | | | (1.30; 2.89)*
| | Vacuum delivery | | 1.26 (0.77; 2.07)
Macarthur, 2005 ^215^ | | Number of births, ≥4 | 6 years postpartum | 2.12
N = 4,046 | | | | (1.34; 3.35)*
| | Number of births, 1 | | 1.00 (1.00; 1.00)
| | Number of births, 3 | | 1.61
| | | | (1.08; 2.41)*
| | Number of births, 2 | | 1.23 (0.85; 1.78)
| | ≥1 forceps | | 1.48
| | | | (1.18; 1.87)*
| | Only Caesarean section(s) | | 1.04 (0.72; 1.50)
Bharucha, 2006 ^225^ | ≥20 | Cesarean section only, no surgery | | 0.7 (0.3; 1.5)
N = 2,800 | | Vaginal delivery with forceps or stitches, no surgery | | 1.2 (0.9; 1.6)
| | Vaginal delivery without forceps or stitches, no surgery | | 0.8 (0.5; 1.1)
Signorello, 2000 ^697^ | | Episiotomy vs. 2nd/3rd/4th degree tear | 3 months postpartum | 3.20
N = 626 | | | | (1.30; 7.90)*
| | | 6 months postpartum | 2.90
| | | | (0.70; 11.20)
| | Episiotomy vs. intact/1st degree tear | 3 months postpartum | 5.50
| | | | (1.80; 16.20)*
| | | 6 months postpartum | 3.70
| | | | (0.90; 15.60)
Meyer, 2000 ^700^ | 29 | Forceps delivery vs. spontaneous delivery | 10 month after delivery | 0.80 (0.75; 1.05)
N = 107
Schraffordt Koops, 2003 ^701^ | | Forceps delivery vs. spontaneous delivery | Incident 3–4 years after delivery | 1.25 (0.69; 2.27)
N = 479 | | | 3–4 years after delivery | 0.80 (0.44; 1.44)
Mahony, 2007 ^230^ | 18–46 | Instrumental delivery | | 3.10
N = 500 | | | | (1.20; 7.90)*
| | Internal anal sphincter defect thickness; partial (1 quadrant) | | 2.10 (0.50; 10.70)
| | Internal anal sphincter defect thickness; partial (>1 quadrant) or full thickness | | 5.10 (1.50; 22.90)*
| | Parity >3 | | 1.40 (0.30; 5.50)
| | Parity 2 | | 1.70 (0.60; 4.90)
Ostbye, 2004 ^186^ | >65 | Number of children: ≥4 | Prevalence | 0.81 (0.49; 1.36)
N = 8,949 | | | Incidence | 0.79 (0.55; 1.14)
| | Number of children: 3 | Prevalence | 1.25 (0.73; 2.12)
| | | Incidence | 0.78 (0.51; 1.18)
| | Number of children: 2 | Prevalence | 1.03 (0.62; 1.73)
| | | Incidence | 0.89 (0.6; 1.31)
| | Number of children: 1 | Prevalence | 1.07 (0.59; 1.95)
| | | Incidence | 0.92 (0.58; 1.45)
Borello-France, 2006 ^231^ | | Sphincter tear | At 6 weeks postpartum | 2.8 (1.8; 4.3)*
N = 721 | | | At 6 months postpartum | 1.9 (1.2; 3.2)*
Borello-France, 2006 ^231^ | | Vaginal control | At 6 weeks postpartum | 1.1 (0.49; 2.5)
N = 472 | | | At 6 months postpartum | 1.01 (0.38; 2.71)
Richter, 2006 ^706^ | | Sphincter tear vs. vaginal delivery without anal sphincter tear | 6–12 months after delivery | 4.40
N = 251 | | | | (1.60; 12.30)*
| | 3^rd^ vs. 4^th^ degree tear of anal sphincter | 6–12 months after delivery | 2.00 (0.70; 5.80)
Schraffordt Koops, 2003 ^701^ | | Vacuum extraction vs. spontaneous delivery | Incident 3–4 years after delivery | 0.85 (0.48; 1.51)
N = 479 | | | 3–4 years after delivery | 1.18 (0.66; 2.09)
MacLennan, 2000 ^7^ | 42.9 | Vaginal vs. caesarean delivery | | 1.50 (0.50; 4.90)
N = 3,010
Fecal Soiling
Peschers, 2003 ^694^ | 34 | Vacuum vs. spontaneous vaginal delivery | 6–24 weeks postpartum | 0.68 (0.20; 2.32)
N = 100
Flatus
Chaliha, 1999 ^205^ | 17–46 | Augmentation | 3 months postpartum | 0.8 (0.2; 2.8)
N = 549 | | Epidural analgesia | 3 months postpartum | 0.9 (0.7; 1.3)
| | Fetal head circumference | 3 months postpartum | 0.9 (0.6; 1.2)
| | Fetal weight | 3 months postpartum | 2.9 (0.8; 10.2)
| | First stage (reference) | 3 months postpartum | 1
| | Mode of delivery | 3 months postpartum | 1.1 (0.6; 2.2)
| | Perineal trauma | 3 months postpartum | 1 (1; 1)
| | Second stage (active) | 3 months postpartum | 1 (1; 1)
| | Second stage (passive) | 3 months postpartum | 1 (1; 1)
Chaliha, 1999 ^205^ | 17–46 | Didn't receive labor epidural | 3 months postpartum | 1 (1; 1)
N = 549
Signorello, 2000 ^697^ | | 2nd/3rd/4th degree tear v intact/1st degree tear | 3 months postpartum | 0.80 (0.50; 1.40)
N = 626 | | | 6 months postpartum | 1.10 (0.50; 2.10)
Wagenius, 2003 ^693^ | | Anal sphincter rupture following vaginal delivery | 4 years after delivery | 2.71
N = 654 | | | | (1.78; 4.15)*
Abramov, 2005 ^226^ | 26–86 | At least 1 episiotomy | | 1.22 (0.7; 2.11)
N = 274 | | At least 1 forceps delivery | | 0.76 (0.33; 1.21)
| | At least 1 prolonged second stage of labor (>2 hours) | | 1.04 (0.58; 1.78)
| | At least 1 birth weight >4kg | | 1.02 (0.63; 1.63)
Abramov, 2005 ^226^ | 26–86 | Cesarean only | | 0.92 (0.52; 1.56)
N = 346
Abramov, 2005 ^226^ | 26–86 | Parity ≥2 | | 2.72
N = 542 | | | | (1.65; 4.51)*
| | Parity, 1 | | 2.27
| | | | (1.28; 4.05)*
Borello-France, 2006 ^231^ | | Cesarean control | At 6 weeks postpartum | 1 (1; 1)
N = 472 | | | At 6 months postpartum | 1 (1; 1)
Borello-France, 2006 ^231^ | | Sphincter tear | At 6 weeks postpartum | 1.6 (1.1; 2.4)*
N = 721 | | | At 6 months postpartum | 1.7 (1.1; 2.7)*
Borello-France, 2006 ^231^ | | Vaginal control, n = 721 | At 6 weeks postpartum | 1 (1; 1)
| | Vaginal control, n = 472 | At 6 weeks postpartum | 1.3 (0.67; 2.6)
| | Vaginal control, n = 721 | At 6 months postpartum | 1 (1; 1)
| | Vaginal control, n = 472 | At 6 months postpartum | 0.48 (0.24; 0.96)*
Uustal Fornell, 2004 ^185^ | >40 | Delivery by vacuum extractor | | 1.40 (0.50; 4.50)
N = 885 | | Large tear at delivery | | 1.80 (1.00; 3.30)
| | Sphincter rupture | | 6.10
| | | | (2.30; 16.50)*
| | 3 or more births | | 0.90 (0.60; 1.40)
| | Vaginal delivery | | 1.10 (0.40; 3.00)
| | | | 1.50 (0.80; 2.70)
Signorello, 2000 ^697^ | | Episiotomy vs. 2nd/3rd/4th degree tear | 3 months postpartum | 2.10
N = 626 | | | | (1.30; 3.40)*
| | | 6 months postpartum | 2.10
| | | | (1.20; 3.70)*
| | Episiotomy vs. intact/1st degree tear | 3 months postpartum | 1.70 (1.00; 2.80)
| | | 6 months postpartum | 2.30
| | | | (1.20; 4.30)*
van Brummen, 2006 ^662^ | 30 | Flatus incontinence at 12 weeks gestation | 1 years postpartum | 6.82 (4.20; 11.00)*
N = 487
Peschers, 2003 ^694^ | 34 | Vacuum vs. spontaneous vaginal delivery | 6–24 weeks postpartum | 1 (0.375; 2.664)
N = 100
MacLennan, 2000 ^7^ | 42.9 | Vaginal vs. Caesarean delivery | | 1.80 (0.80; 3.80)
N = 3,010
Liquid Feces Incontinence
Uustal Fornell, 2004 ^185^ | >40 | Delivery by vacuum extractor | | 2.00 (0.70; 6.00)
N = 885 | | Large tear at delivery | | 2.70
| | | | (1.30; 5.50)*
| | Sphincter rupture | | 4.20 (1.60; 11.30)*
| | 3 or more births | | 1.00 (0.70; 1.50)
| | Vaginal delivery | | 0.80 (0.30; 2.10)
| | | | 1.00 (0.50; 1.80)
Peschers, 2003 ^694^ | 34 | Vacuum vs. spontaneous vaginal delivery | 6–24 weeks postpartum | 1 (0.236; 4.241)
N = 100
Wagenius, 2003 ^693^ | | Anal sphincter rupture following vaginal delivery | 5 years after delivery | 3.29
N = 654 | | | | (1.93; 5.60)*
Solid Feces Incontinence
Wagenius, 2003 ^693^ | | Anal sphincter rupture following vaginal delivery | 6 years after delivery | 1.91 (0.71; 5.17)
N = 654
Uustal Fornell, 2004 ^185^ | >40 | Delivery by vacuum extractor | | 1.20 (0.00; 7.50)
N = 885 | | Large tear at delivery | | 2.90 (0.60; 14.60)
| | Sphincter rupture | | 9.10 (3.00; 27.30)*
| | 3 or more births | | 1.10 (0.50; 2.30)
| | Vaginal delivery | | 1.00 (0.30; 2.70)
Peschers, 2003 ^694^ | 34 | Vacuum vs. spontaneous vaginal delivery | 6–24 weeks postpartum | 3.13 (0.31; 31.14)
N = 100

Bold - multivariate odds ratios

* Significant difference

Table 41 Association between risk of FI and severity of FI and factors related to pregnancy and birth

Author | Age | Fecal Incontinence | Factors Related to Pregnancy and Birth | Time From Exposure to Outcome | Odds Ratio
Sample | | | | | (95% CI)
Chaliha, 1999 ^205^ | 17–46 | Fecal urgency | Augmentation | 3 months postpartum | 0.6 (0.2;1.6)
N = 549 | | | Epidural analgesia | | 0.4 (0.1; 1.4)
| | | Fetal head circumference | | 1 (0.7; 1.4)
| | | Fetal weight | | 1 (0.6; 6.8)
| | | First stage (reference) | | 1 (1; 1)
| | | Mode of delivery | | 0.8 (0.6; 1.2)
| | | No perineal trauma | | 1 (1; 1)
| | | Perineal trauma | | 0.9 (0.5; 1.8)
| | | Second stage (active) | | 1 (1; 1)
| | | Second stage (passive) | 3 months postpartum | 1 (1; 1)
Pregazzi, 2002 ^704^ | 21–43 | Abnormal results of pelvic floor muscle assessment; digital test | Anal sphincter and rectal mucosa tears vs. intact perineum and superficial tears | Immediately after vaginal delivery | 1.04 (0.24; 4.49)
N = 218
| | Abnormal results of pelvic floor muscle assessment; vaginal manometry | Anal sphincter and rectal mucosa tears vs. intact perineum and superficial tears | immediately after vaginal delivery | 0.91 (0.18; 4.69)
Faltin, 2001 ^232^ | 15–93 | Fecal urgency | Anal sphincter tear | | 2.8( 0.9; 9.1)
N = 1,228 | | | Baby weight, ≤4,000g | | 1 (1; 1)
| | | Baby weight, >4,000g | | 1.5 (0.7; 3.1)
Borello-France ^231^ | | Fecal urgency | Cesarean control | 6 weeks postpartum | 1 (1;1)
N = 472
Sultan, 1993 ^699^ | | Urgency | Forceps delivery | | 7.23 (0.85; 61.35)
N = 90
Liebling, 2004 ^707^ | | Pain on opening bowels | Instrumental delivery vs. Cesarean | 6 weeks postpartum | 1.34 (0.74; 2.42)
N = 393 | | Constipation | Instrumental delivery vs. Cesarean | 6 weeks postpartum | 0.85 (0.48; 1.49)
| | Increased passage of flatus | Instrumental delivery vs. Cesarean | 6 weeks postpartum | 1.44 ( 0.87; 2.39)
| | Hemorrhoids | Instrumental delivery vs. Cesarean | 6 weeks postpartum | 1.34 ( 0.80; 2.26)
| | Loss of control of bowels | Instrumental delivery vs. Cesarean | 6 weeks postpartum | 1.25 (0.28; 5.63)
| | Pain on opening bowels | | 1 year postpartum | 1.53 (0.44; 5.36)
| | Constipation | | | 2.55 (1.02; 6.37)*
| | Increased passage of flatus | | | 1.66 (0.88; 3.12)
| | Hemorrhoids | | | 1.70 (0.92; 3.14)
| | Loss of control of bowels | | | 1.74 (0.34; 8.87)
Faltin, 2001 ^232^ | 15–93 | Fecal urgency | Operative delivery | | 1 (0.5; 2.2)
N = 1,228 | | | Parity | | 2.7 (1.1; 6.8)*
Pregazzi, 2002 ^704^ | 21–43 | Abnormal results of pelvic floor muscle assessment: digital test | Perineal muscle tears vs. intact perineum and superficial tears | Immediately after vaginal delivery | 1.82 (0.90; 3.67)
N = 218 | | Abnormal results of pelvic floor muscle assessment: vaginal manometry | | | 1.53 (0.73; 3.20)
Borello-France, 2006 ^231^ | | Fecal urgency | Sphincter tear | At 6 weeks postpartum | 1.5 (1.1; 2.1)*
N = 721, | | | | At 6 months postpartum | 1.5 (1.02; 2.2)
Peschers, 2003 ^694^ | 34 | Fecal urgency | Vacuum vs. spontaneous vaginal delivery | 6–24 weeks postpartum | 1 (0.24; 4.24)
N = 100
Borello-France, 2006 ^231^ | | Fecal urgency | Vaginal control | At 6 weeks postpartum | 0.67 (0.39; 1.13)
N = 472 | | | | At 6 months postpartum | 1 (1; 1)
| | | | At 6 months postpartum | 0.53 (0.29; 0.93)*
Faltin, 2006 ^695^ | | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | Birth weight, >4,000g | 18 years after rupture of anal sphincter tear during childbirth | 1.21 (0.47; 3.14)
N = 240 | | | Birth weight, 3,000–3,499g | 18 years after rupture of anal sphincter tear during childbirth | 0.74 (0.39; 1.4)
| | | Birth weight, 3,500–3,999g | 18 years after rupture of anal sphincter tear during childbirth | 0.86 (0.44; 1.68)
| | | No episiotomy | 18 years after rupture of anal sphincter tear during childbirth | 1 (1; 1)
| | | Episiotomy | 18 years after rupture of anal sphincter tear during childbirth | 1.04 (0.93; 1.15)
Guise, 2007 ^218^ | | Severity, incontinence of stool | Cesarean in this delivery | | 0.94 (0.77; 1.15)
N = 8,774 | | | Cesarean in this delivery, labored without push | | 0.81 (0.53; 1.25)
| | | Cesarean in this delivery, never labored | | 1 (1; 1)
| | | Cesarean labored and pushed | | 0.92 (0.56; 1.52)
| | | Ever had Cesarean | | 0.92 (0.76; 1.11)
| | | Forceps use, ever | | 1.29 (0.98; 1.7)
Faltin, 2006 ^695^ | | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | Multiparity | 18 years after rupture of anal sphincter tear during childbirth | 0.99 (0.53; 1.85)
N = 240 | | | Non Cesarean delivery | 18 years after rupture of anal sphincter tear during childbirth | 1 (1; 1)
| | | Non operative vaginal delivery | 18 years after rupture of anal sphincter tear during childbirth | 1 (1; 1)
| | | Primiparity | 18 years after rupture of anal sphincter tear during childbirth | 1 (1; 1)
Guise, 2007 ^218^ | | Severity, incontinence of stool | Pushing time ≥1 hour in this delivery | | 1.22 (1.02; 1.47)
N = 8,774 | | | This infant weight, ≥4,000g | | 0.92 (0.73; 1.15)
| | | Vacuum only, ever | | 1.12 (0.88; 1.42)
| | | ≥3 parity | | 1.03 (0.84; 1.27)
| | | 1 parity | | 1 (1; 1)
| | | 2 parity | | 0.9 (0.75; 1.09)
MacArthur, 2001 ^214^ | 42.9 | Frequent FI | Caesarean section | 3 months postpartum | 0.36 (0.14; 0.98)*
N = 7,879
Macarthur, 2005 ^215^ | | Persistent FI | Caesarean section | 6 years postpartum among primiparae at index delivery. | 0.56 (0.23; 1.37)
N = 4,046 | | Persistent FI | Caesarean section | 6 years postpartum | 1.07 (0.64; 1.81)
Faltin, 2006 ^695^ | | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | Cesarean delivery | 18 years after rupture of anal sphincter tear during childbirth | 0.61 (0.16; 2.38)
N = 240
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Episiotomy | At 16 weeks of gestation in the index-pregnancy | 1.9 (0.8, 4.2)
Sultan, 1993 ^699^ | | Fecal and urgency | Forceps delivery | | 19.56
N = 90 | | | | | (1.12; 340.25)*
MacArthur, 2001 ^214^ | 42.9 | Frequent FI | Forceps delivery | 3 months postpartum | 1.94 (1.07; 3.54)*
N = 7,879
Macarthur, 2005 ^215^ | | Persistent FI | Forceps delivery | 6 years postpartum among primiparae at index delivery. | 2.50 (1.37; 4.59)*
N = 4,046 | | | | 6 years postpartum | 2.06 (1.40; 3.04)*
Schraffordt Koops, 2003 ^701^ | | FI, Grade 2 | Forceps delivery vs. spontaneous delivery | 3–4 years after delivery | 0.67 (0.22; 2.01)
N = 479 | | FI, Grade 3 | Forceps delivery vs. spontaneous delivery | 3–4 years after delivery | 1.23 (0.46; 3.30)
| | FI, Grade 4 | Forceps delivery vs. spontaneous delivery | 3–4 years after delivery | 1.68 (0.74; 3.81)
Guise, 2007 ^218^ | | Severity, incontinence of stool | Forceps use, this delivery | | 1.66 (1.1; 2.5)*
N = 8,774 | | | Heaviest infant weight, ≥4,000g | | 0.85 (0.69; 1.04)
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | infant weight, <4,000g | At 16 weeks of gestation in the index-pregnancy | 1 (1; 1)
| | | Infant weight, ≥4,000g | At 16 weeks of gestation in the index-pregnancy | 2.4 (1.1; 5.1)*
Guise, 2007 ^218^ | | Severity, incontinence of stool | Laceration, cut/tear with anus injury in this delivery | | 2.31 (1.61; 3.32)*
N = 8,774 | | | Laceration, cut/tear with no/unknown anus injury in this delivery | | 1.06 (0.89; 1.26)
| | | Laceration, ever had cut/tear with anus injury | | 1.61 (1.21; 2.15)*
| | | Laceration, ever had cut/tear with no/unknown anus injury | | 1 (0.81; 1.23)
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Length of second stage >90 minutes | At 16 weeks of gestation in the index-pregnancy | 0.5 (0.1; 2.4)
Macarthur, 2005 ^215^ | | Persistent FI | Number of births, ≥4 | 6 years postpartum among primiparae at index delivery | 3.65 (0.80; 16.60)
N = 4,046 | | | Number of births, ≥4 | 6 years postpartum | 3.22 (1.34; 7.76)*
| | | Number of births -1 | 6 years postpartum among primiparae at index delivery | 1.00 (1.00; 1.00)
| | | Number of births -1 | 6 years postpartum | 1.00 (1.00; 1.00)
| | | Number of births -3 | 6 years postpartum among primiparae at index delivery | 2.57 (0.94; 6.99)
| | | Number of births -3 | 6 years postpartum | 2.91 (1.32; 6.41)*
| | | Number of births -2 | 6 years postpartum among primiparae at index delivery | 2.15 (0.97; 4.79)
| | | Number of births -2 | 6 years postpartum | 2.13 (1.00; 4.52)
Nichols 2005 ^679^ 2 | 53 | Bothersome FI | Operative delivery vs. vaginal delivery in stage II pelvic organ prolapse and/or UI | | 4.50 (1.20; 17.10)*
N = 190 | | | Operative vaginal delivery pelvic floor disorders vs. not operative delivery | | 3.60 (1.60; 8.80)*
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Outlet forceps | At 16 weeks of gestation in the index-pregnancy | 3.5 (0.4; 30.2)
Faltin, 2006 ^695^ | | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | Overactive vaginal delivery | 18 years after rupture of anal sphincter tear during childbirth | 1.83 (1.11; 3.02)*
N = 240
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Oxytocin stimulation | At 16 weeks of gestation in the index-pregnancy | 0.7 (0.4; 1.5)
| | | Parity, ≥3 caesarean section only | | N/A
| | | Parity, ≥3 vaginal delivery only | | 1.3 (0.6; 2.4)
| | | Parity, 0 | | 1 (1; 1)
| | | Parity, 1, first delivery caesarean section | | 0.7 (0.3; 1.6)
| | | Parity, 2, caesarean section only | | 2.5 (0.3; 20.7)
| | | Parity, 2, vaginal delivery only | | 0.8 (0.5; 1.3)
| | | Parity, vaginal delivery | | 0.9 (0.7; 1.2)
| | | Pudendal block | | 0.6 (0.3; 1.2)
Guise, 2007 ^218^ | | Severity, incontinence of stool | Pushing time ever ≥1 hour | | 1.07 (0.91; 1.26)
N = 8,774
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Spontaneous perineal rupture | At 16 weeks of gestation in the index-pregnancy | 1.2 (0.4; 3.8)
| | | 3rd degree anal sphincter tear | | 6.3 (1.1; 37.4)*
| | | Time since last delivery ≤1 year | | 0.5 (0.1; 4.3)
| | | Time since last delivery >1 year | | 1 (1; 1)
MacArthur, 2001 ^214^ | 42.9 | Frequent FI | Vacuum delivery | 3 months postpartum | 1.29 (0.62; 2.71)
N = 7,879
Macarthur, 2005 ^215^ | | Persistent FI | Vacuum delivery | 6 years postpartum among primiparae at index delivery | 0.41 (0.10; 1.75)
N = 4,046 | | | | 6 years postpartum | 0.47 (0.15; 1.53)
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Vacuum extraction | At 16 weeks of gestation in the index-pregnancy | 1.5 (0.6; 3.9)
Schraffordt Koops, 2003 ^701^ | | FI Grade 2 | Vacuum extraction vs. spontaneous delivery | 3–4 years after delivery | 0.97 (0.39; 2.41)
N = 479 | | FI Grade 3 | | | 0.97 (0.37; 2.52)
Guise, 2007 ^218^ | | Severity, incontinence of stool | Vacuum only, this delivery | | 1.12 (0.82; 1.53)
N = 8,774
Peschers, 2003 ^694^ | 34 | Flatus incontinence >1/week | Vacuum vs. spontaneous vaginal delivery | 6–24 weeks postpartum | 1.741 (0.39; 7.713)
N = 100 | | Incontinence for liquid stood >1/week | | | 7.442 (0.37; 147.9)
| | Incontinence for solid stool >1/week | | | 3.061 (0.12; 76.95)
Hojberg, 2000 ^227^ | ≥15 | Severity, isolated flatus incontinence at least once a week | Vaginal rupture | At 16 weeks of gestation in the index-pregnancy | 0.8 (0.4; 1.8)
Schraffordt Koops, 2003 ^701^ | | FI Grade 4 | Vacuum extraction vs. spontaneous delivery | 3–4 years after delivery | 0.71 (0.29; 1.74)
N = 479

Bold - multivariate odds ratios

* Significant difference

Fetal characteristics were examined in association to FI in 11 studies (Appendix Table F56). ^202,^ ^205,^ ^218,^ ^226^ – ^228,^ ^232,^ ^662,^ ^689,^ ^692,^ ^695^ Fetal weight was associated with random changes in AI ^205,^ ^228,^ ^232,^ ^692^ and FI, ^662,^ ^689^ but with a significant increase in the adjusted odds of FI by 240 percent in one study of 3,887 women. ^202^ Head circumference of the baby did not show a significant relationship with FI ^205,^ ^692^ or fecal urgency. ^205^

Women with FI during pregnancy experienced higher rates of FI after delivery (Table 42). ^209,^ ^662^ Women with narrow subpubic arch angle experienced FI almost nine times more often independent of other risk factors. ^692^ The number of births associated with FI was examined in 18 studies, ^163,^ ^185,^ ^186,^ ^208,^ ^212,^ ^218,^ ^227,^ ^229,^ ^230,^ ^657,^ ^658,^ ^695,^ ^696^ but only five found a significant increase in odds of FI independent on other risk factors. ^209,^ ^213,^ ^215,^ ^226,^ ^232^ Women giving birth had FI three times more often compared to childless females. ^232^ Four studies reported dose response associations between FI and the number of births. ^209,^ ^213,^ ^215,^ ^226^ Adjusted odds of persistent FI were 3.2 times greater among women after four or more deliveries. ^215^

Table 42 Association between baseline FI, number of pregnancies and FI

Author | Definition of FI | Risk Factors | Time Since Exposure to FI | Odds Ratio
Sample | | | | (95% CI)
Zetterstrom, 1999 ^703^ | AI | 10 increase in maternal age | 9 months postpartum | 3.00 (1.40; 6.40)*
N = 349
Mazouni, 2005 ^689^ | FI | Incremental increase in maternal age | 12 months after instrumental delivery | 1.00 (1.00; 1.00)
N = 159
Pollack, 2004 ^209^ | AI | AI at 5 months of pregnancy | 5 years after vaginal delivery | 3.80 (2.00; 7.30)*
N = 349 | | AI at 9 months of pregnancy | | 4.30 (2.20; 8.20)*
| | Subsequent childbirth | | 2.40 (1.10; 5.60)*
van Brummen, 2006 ^662^ | FI | FI at 12 weeks gestation | 1 year after delivery | 2.60 (0.90; 12.10)
N = 487 | Flatus | Flatus incontinence at 12 weeks gestation | 1 year postpartum | 6.82 (4.20; 11.00)*
McKinnie, 2005 ^657^ | FI | Any term pregnancy vs. no term pregnancy | | 2.26 (1.22; 4.19)*
N = 1,004 | | >1 pregnancy and >1 vaginal delivery vs. no vaginal delivery | | 2.15 (0.97; 4.77)
| | >1 pregnancy and >1 vaginal delivery vs.>1 pregnancy, no vaginal delivery | | 1.93 (0.81; 4.60)
| | >1 pregnancy and >1 vaginal delivery vs. no term pregnancy | | 2.41 (1.30; 4.49)*
| | >1 pregnancy and vaginal delivery vs. no term pregnancy | | 1.13 (0.43; 2.96)
| | >1 pregnancy vs. no term pregnancy | | 1.35 (0.69; 5.74)
Faltin, 2006 ^695^ | Severity, at least 2 symptoms at least once a week or 3 symptoms (flatus, liquid or solid stool; pad use; lifestyle alteration) | Multiparity | 18 years after rupture of anal sphincter tear during childbirth | 0.99 (0.53; 1.85)
N = 240
Faltin, 2001 ^696^ | AI | Delivery again | | 1 (1; 1)
| | No subsequent delivery | | 2.8 (1; 8.3)
Faltin, 2001 ^232^ | FI | Parity | | 3.1 (1.6; 6)*
N = 1,228 | Fecal urgency | Parity | | 2.7 (1.1; 6.8)*
Chiarelli, 2003 ^658^ | FI | Multiparity | At 12 months postpartum | 1.42 (0.53; 3.83)
N = 568
Boreham, 2005 ^212^ | AI | Nulliparity | | 0.63 (0.4; 0.99)*
N = 457
De Leeuw, 2001 ^229^ | FI | Primiparity, without episiotomy | After anal sphincter damage during delivery | 1.16 (0.41; 3.29)
N = 250
Melville, 2005 ^163^ | FI | Nulliparity | | 1.35 (0.88; 2.08)
N = 6,888
Guise, 2007 ^218^ | Severity, incontinence of stool | ≥3 parity | | 1.03 (0.84; 1.27)
N = 8,774 | Solid feces | 1 parity | | 1 (1; 1)
| | 2 parity | | 0.9 (0.75; 1.09)
Macarthur, 2005 ^215^ | FI | Number of births: ≥4 | 6 years postpartum | 2.12 (1.34; 3.35)*
N = 4,046 | Persistent FI | | 6 years postpartum among primiparae at index delivery | 3.65 (0.80; 16.60)
| | | 6 years postpartum | 3.22 (1.34; 7.76)*
| FI | Number of births: 1 | 6 years postpartum | 1.00 (1.00; 1.00)
| Persistent FI | | 6 years postpartum among primiparae at index delivery | 1.00 (1.00; 1.00)
| | | 6 years postpartum | 1.00 (1.00; 1.00)
| FI | Number of births: 3 | 6 years postpartum | 1.61 (1.08; 2.41)
| Persistent FI | | 6 years postpartum among primiparae at index delivery | 2.57 (0.94; 6.99)
| | | 6 years postpartum | 2.91 (1.32; 6.41)*
| FI | Number of births: 2 | 6 years postpartum | 1.23 (0.85; 1.78)
| Persistent FI | | 6 years postpartum among primiparae at index delivery. | 2.15 (0.97; 4.79)
| | | 6 years postpartum | 2.13 (1.00; 4.52)
Richter, 2005 ^208^ | AI | Number of children | Morbid obesity before laparoscopic weight loss surgery | 1.11 (0.86; 1.44)
N = 180 | | Number of vaginal deliveries | Morbid obesity before laparoscopic weight loss surgery | 1.18 (0.92; 1.53)
Ostbye, 2004 ^186^ | FI | Number of children: ≥4 | Prevalence | 0.81 (0.49; 1.36)
N = 8,949 | | | Incidence | 0.79 (0.55; 1.14)
| | Number of children: 3 | Prevalence | 1.25 (0.73; 2.12)
| | | Incidence | 0.78 (0.51; 1.18)
| | Number of children: 2 | Prevalence | 1.03 (0.62; 1.73)
| | | Incidence | 0.89 (0.6; 1.31)
| | Number of children: 1 | Prevalence | 1.07 (0.59; 1.95)
| | | Incidence | 0.92 (0.58; 1.45)
Uustal Fornell, 2004 ^185^ | AI | 1–2 births | | 1.00 (1.00; 1.00)
N = 885 | Flatus | 3 or more births | | 0.90 (0.60; 1.40)
| Liquid feces | | | 1.00 (0.70; 1.50)
| Solid feces | | | 1.10 (0.50; 2.30)
Chen, 2003 ^213^ | AI | Parity ≥1 | | 3.4 (1.2; 9.5)*
N = 1,253
Abramov, 2005 ^226^ | FI | Parity ≥2 | | 3.09 (1.25; 7.65)*
N = 542 | Flatus | Parity ≥2 | | 2.72 (1.65; 4.51)*
| FI | Parity, 1 | | 1.32 (1; 2.3)
| Flatus | Parity, 1 | | 2.27 (1.28; 4.05)*
Mahony, 2007 ^230^ | FI | Parity >3 | | 1.40 (0.30; 5.50)
N = 500 | | Parity 2 | | 1.70 (0.60; 4.90)
Hojberg, 2000 ^227^ | Severity, isolated flatus incontinence at least once a week | Parity, ≥3 Caesarean section only | | N/A
| | Parity, ≥3 vaginal delivery only vs. parity, 0 | | 1.3 (0.6; 2.4)
| | Parity, 1, first delivery Caesarean section | | 0.7 (0.3; 1.6)
| | Parity, 2; Caesarean section only | | 2.5 (0.3; 20.7)
| | Parity, 2, vaginal delivery only | | 0.8 (0.5; 1.3)
| | Parity, vaginal delivery | | 0.9 (0.7; 1.2)
| | Time since last delivery ≤1 year | At 16 weeks of gestation in the index-pregnancy | 0.5 (0.1; 4.3)
| | Time since last delivery >1 year | At 16 weeks of gestation in the index-pregnancy | 1 (1; 1)
Frudinger, 2002 ^692^ | AI | Narrow subpubic arch angle vs. normal subpubic arch angle | | 8.69 (3.15; 23.94)*
N = 134

Bold - multivariate odds ratios

* Significant difference

The association between FI and delivery management was examined in several studies (Appendix Table F57). Mediolateral episiotomy after the first pregnancy was associated with lower odds by 83 percent of FI in one study ^229^ of seven. ^202,^ ^227^ – ^229,^ ^695,^ ^697^ Prolonged pushing time was associated with 22 percent higher odds of solid FI. ^218^ Cesarean surgery was shown to reduce the risk of FI by 42 percent and frequent FI by 64 percent in one study ^214^ of 14. ^163,^ ^185,^ ^202,^ ^205,^ ^208,^ ^214,^ ^215,^ ^218,^ ^225,^ ^226,^ ^228,^ ^692,^ ^695,^ ^698^ Forceps delivery was associated with increased adjusted odds of FI in one multicenter study ^215^ with random results in others. ^202,^ ^214,^ ^215,^ ^218,^ ^226^ – ^228,^ ^692,^ ^699^ – ^701^ An inconsistent increase in FI was shown after instrumental delivery in one study. ^230^ The operative delivery in women with stage II pelvic organ prolapse and/or UI was associated with a 4.5 times greater adjusted odds of bothersome FI. ^679^ Vacuum extraction did not show a significant association with postpartum FI. ^214,^ ^215,^ ^218,^ ^227,^ ^694,^ ^701^ Vaginal delivery was not shown as a significant risk factor for FI. ^7,^ ^163,^ ^185,^ ^210,^ ^212,^ ^213,^ ^225,^ ^229,^ ^231,^ ^695^

Birth related perianal trauma was associated with a large increase in adjusted rates of FI in eight of 24 studies (Table 43) ^187,^ ^209,^ ^218,^ ^228^ – ^232^ Women with sphincter tears had 230 percent ^209^ to 280 percent ^231,^ ^232^ higher rates of FI. The degree of perineal damage showed dose response association with FI. ^229,^ ^230^ Women with stage IV perineal damage experienced FI more often compared to damage of grades I–II. ^228,^ ^229^ Full thickness of the internal anal sphincter defect was associated with 510 percent higher rates of FI after adjustment for other risk factors. ^230^

Table 43 Association between FI and birth related anal trauma

Author | Risk Factor | Fecal Incontinence | Time from Exposure to FI | Odds Ratio
Sample | | | | (95% CI)
Borello-France, 2006 ^231^ | Sphincter tear | FI | 6 weeks postpartum | 2.8 (1.8; 4.3)*
N = 721 | | | 6 months postpartum | 1.9 (1.2; 3.2)*
| | FI urgency | 6 weeks postpartum | 1.5 (1.1; 2.1)*
| | | 6 months postpartum | 1.5 (1.02; 2.2)*
| | Flatus | 6 weeks postpartum | 1.6 (1.1; 2.4)*
| | | 6 months postpartum | 1.7 (1.1; 2.7)*
Casey 2005 ^202^ | 3rd-or 4th-Degree laceration | AI | Within 7 months of delivery, at or before their 6-month contraceptive followup after delivery | 1 (0.5; 2)
N = 3,887
Chaliha, 1999 ^205^ | Perineal trauma | FI urgency | 3 months postpartum | 0.9 (0.5; 1.8)
N = 549 | | Flatus | 3 months postpartum | 1 (1; 1)
Chiarelli, 2003 ^658^ | No perineal trauma | FI | 12 months postpartum | 1 (1; 1)
N = 568 | Perineal trauma (tear with sutures and/or episiotomy) | FI | 12 months postpartum | 1.67 (0.67; 4.14)
De Leeuw, 2001 ^229^ | Extent of perineal damage (per grade: grade-IV vs. grade-IIIb vs. grade-IIIa) | FI | After anal sphincter damage during delivery | 2.54
N = 250 | | | | (1.45; 4.45)*
| Primiparity, with episiotomy | FI | After anal sphincter damage during delivery | 0.15
| | | | (0.02; 0.98)
Eason, 2002 ^228^ | First-degree tear perineal injury | AI | 3 months postpartum | 1.2 (0.8; 1.7)
N = 252 | 3^rd^ or 4^th^ degree tear perineal injury | | | 2.1 (1.4; 3.1)*
Faltin ^696^ | External and internal anal sphincter defect | AI | 3 months after delivery | 7.4 (1.7; 31.4)*
N = 100 | | | 30 months after delivery | 5.3 (1.2; 24.1)*
| Isolated external anal sphincter defect | AI | 3 months after delivery | 6.2 (1.2; 32)*
| | | 30 months after delivery | 6.5 (1.3; 33.4)*
| | | 3 months after delivery | 1.9 (0.2; 18.7)
Faltin, 2001 ^232^ 2 | Anal sphincter tear | FI urgency | | 2.8 (0.9; 9.1)
N = 1,228
Faltin, 2001 ^696^ | Anal sphincter tear | AI | 3 months after delivery | 4.3 (1.9; 9.7)**
N = 100 | (clinically diagnosed) | | 30 months after delivery | 3.4 (1.2; 9.8)*
| Clinically occult anal sphincter tears | | 3 months after delivery | 3.8 (0.8; 17.1)
| | | 30 months after delivery | 7.7 (1; 60.1)
| Sphincter defects diagnosed after endosonography 3 months after delivery | AI | Transient shortly after delivery | 2 (1.4; 2.8)*
| | | 3 months after delivery | 1.9 (1.4; 2.6)*
| | | 30 months after delivery | 1.9 (1.3; 2.8)*
Frudinger, 2002 ^692^ | No ultrasonic evidence of injury | AI | | 1 (1; 1)
N = 134 | Ultrasonic evidence of injury, perineal scar | | | 2.69
| | | | (0.7; 10.33)
| Ultrasonic evidence of injury, sphincter scar | | | 2.26
| | | | (0.69; 7.36)
Guise, 2007 ^218^ | Laceration, cut/tear with anus injury in this delivery | Severity, incontinence of stool | | 2.31
N = 8,774 | | | | (1.61; 3.32)*
| Laceration, cut/tear with no/unknown anus injury in this delivery | | | 1.06
| | | | (0.89; 1.26)
| Laceration, ever had cut/tear with anus injury | | | 1.61
| | | | (1.21; 2.15)*
| Laceration, ever had cut/tear with no/unknown anus injury | | | 1 (0.81; 1.23)
| Laceration, no cut/tear ever | | | 1 (1; 1)
| Laceration, no cut/tear in this delivery | | | 1 (1; 1)
Hojberg, 2000 ^227^ | No spontaneous perineal rupture | Severity, isolated flatus incontinence at least once a week | At 16 weeks of gestation in the index-pregnancy | 1 (1; 1)
| No vaginal rupture | | | 1 (1; 1)
| Pudendal block | | | 0.6 (0.3; 1.2)
| Spontaneous perineal rupture | | | 1.2 (0.4; 3.8)
| 3rd degree anal sphincter tear | | | 6.3 (1.1; 37.4)*
| Vaginal rupture | | | 0.8 (0.4; 1.8)
Huang, 2006 ^187^ | History of 3rd or 4th degree vaginal tear, Asian women | AI | | 2.41 (1.14; 5.1)*
| No history of 3rd or 4th degree vaginal tear, Asian women | | | 1 (1; 1)
Mahony, 2007 ^230^ | Internal anal sphincter defect thickness; partial (1 quadrant) | FI | | 2.10
N = 500 | | | | (0.50; 10.70)
| Internal anal sphincter defect thickness; partial (>1 quadrant) or full thickness | | | 5.10
| | | | (1.50; 22.90)
Mazouni, 2005 ^689^ | 3rd-degree tears | FI | 17 months instrumental delivery | 1.00 (1.00; 1.00)
N = 159
Pollack, 2004 ^209^ | Sphincter tear | AI | 5 years after delivery | 2.30
N = 349 | | | | (1.10; 5.00)*
Pregazzi, 2002 ^704^ | Anal sphincter and rectal mucosa tears vs. intact perineum and superficial tears | AI | Immediately after vaginal delivery | 8.78
N = 218 | | | | (2.60; 134.10)*
| | Abnormal results of Pelvic Floor Muscle Assessment: digital test | Immediately after vaginal delivery | 1.04 (0.24; 4.49)
| | Abnormal results of Pelvic Floor Muscle Assessment: vaginal manometry | | 0.91 (0.18; 4.69)
| Perineal muscle tears vs. intact perineum and superficial tears | FI | | 1.48
| | | | (0.10; 14.60)
| | Abnormal results of Pelvic Floor Muscle Assessment: digital test | | 1.82 (0.90; 3.67)
| | Abnormal results of Pelvic Floor Muscle Assessment: vaginal manometry | | 1.53 (0.73; 3.20)
Richter ^706^ | Sphincter tear vs. vaginal delivery without anal sphincter tear | FI | 6–12 months after delivery | 4.40
N = 251 | | | | (1.60; 12.30)*
| 3rd vs. 4th-degree tear of anal sphincter | FI | 6–12 months after delivery | 2.00 (0.70; 5.80)
Signorello, 2000 ^697^ | 2nd/3rd/4th degree tear vs. intact/1st degree tear | FI | 3 months postpartum | 1.40 (0.40; 5.00)
N = 626 | | | 6 months postpartum | 1.20 (0.20; 6.40)
| | Flatus | 3 months postpartum | 0.80 (0.50; 1.40)
| | | 6 months postpartum | 1.10 (0.50; 2.10)
Sultan, 1993 ^705^ | Any anal-sphincter defect after vaginal delivery | FI | | 2.70
N = 124 | | | | (1.97; 3.71)*
Uustal Fornell, 2004 ^185^ | Large tear at delivery | Flatus | | 1.80 (1.00; 3.30)
N = 885 | | Solid | | 2.90
| | | | (0.60; 14.60)
| | Liquid | | 2.70
| | | | (1.30; 5.50)*
| Sphincter rupture | Flatus | | 6.10
| | | | (2.30; 16.50)*
| | Liquid | | 4.20
| | | | (1.60; 11.30)
| | Solid | | 9.10
| | | | (3.00; 27.30)*
van Brummen, 2006 ^662^ | 3rd/4th degree tear | FI | 1 year after delivery | 6.82
N = 487 | | | | (4.20; 11.00)*
Wagenius ^693^ | Anal sphincter rupture following vaginal delivery | Flatus | 4 years after delivery | 2.71
N = 654 | | | | (1.78; 4.15)*
| | Liquid | 5 years after delivery | 3.29
| | | | (1.93; 5.60)*
| | Solid | 6 years after delivery | 1.91 (0.71; 5.17)
Zetterstrom, 1999 ^703^ | Sphincter tear | AI | 9 months postpartum | 2.40
| | | | (1.04; 4.90)*

Bold - multivariate odds ratios

* Significant difference

#### Summary

In conclusion, aging and dependency in daily activities were strongly associated with the development of FI in LTC facilities. Neurological disorders, perineal trauma, and rectal diseases, including neoplasm, are among the independent risk factors of FI in community dwelling adults. Women are at risk of FI related to pregnancy and birth. The strength of the association varied depending on the definitions of FI. Primary prevention of diseases associated with increased risk of FI could reduce the incidence and severity of incontinence in adults. Strategies to reduce the risk of FI related to pregnancy and birth are not well documented and require future research.

## Question 3. What is the Evidence to Support Specific Clinical Interventions to Reduce the Risk of UI and FI?

Baseline mechanisms of incontinence include abnormal detrusor and sphincter functions. Detrusor muscle contraction is regulated by a complex pathway of cholinergic innervations by the pelvic nerves, prostaglandins, and calcium ions. ^22,^ ^23^ A hyperactive bladder would lead to urge UI. Urethral sphincter function is regulated by alpha-adrenergic activity and an anatomically correct position of the urethra in the abdominal cavity to transfer increased abdominal pressure to urethra. Poor urethral sphincter function can result in primary urethral incompetence and stress UI. Effective clinical interventions aim to improve control over bladder contractions, increase strengths of pelvic floor muscles supporting bladder, correct anatomic disposition of dispositional uterus in women, decrease atrophy of tissues and muscles related to estrogen deficiency, and treat injuries due to childbirth.

### Effects of Clinical Interventions on UI in Adults in LTC Settings

#### Implementation of evidence-based guidelines

The implementation of guidance-driven continence care in nursing homes ^238,^ ^708^ did not improve the incontinence status of the residents (Appendix Table F58). The protocol included staff education and direct patient care implemented by advanced practice gerontological nurses in a consecutive cohort of newly admitted residents in three licensed proprietary nursing homes. A quasi-experimental study ^708^ evaluated UI using the Incontinence Monitoring Schedule with frequent observations for 3 days before and after the continence protocol was implemented (Appendix Table F58). The implementation resulted in a nonsignificant tendency to reduce the proportion of incontinence episodes and total prevalence of UI from 71 percent in patients after regular care to 64 percent in the intervention group (Appendix Table F59). ^708^ A multicenter uncontrolled intervention of a computerized quality management model in nursing homes, based on guidelines for medical assessment and individualized prompted voiding protocols of UI, was associated with a nonsignificant reduction in wet episodes among total checks by nurses from 31 to 17 percent. ^238^

#### Conservative management programs

Conservative management programs in nursing homes ^709,^ ^710^ resulted in inconsistent improvement in UI in female residents (Appendix Table F60). Behavioral therapy included hourly wet checks, prompted and assisted toileting, positive reinforcement, and bladder training implemented by trained nursing research assistants. Nursing research assistants reported an improvement in UI in females after active intervention three times more often compared to usual care (26 percent vs. 8 percent, RR 3.1, 95 percent CI 1.3; 7.4) (Appendix Table F61) ^710^ However, the changes in urinary wet episodes were not statistically significant (Appendix Table F62). ^709^ Conservative management programs reduced the progression of UI in the majority of RCTs that included male and female residents of nursing homes (Appendix Table F63). ^233^ – ^237^ The effect size was small and differed depending on the definition of the outcomes. Integrated incontinence care that included fluid prompting, prompted toileting, and regular wet checks in combination with exercises reduced the frequency of UI by 1.6 percent (95 percent CI -2.5;-0.8) compared to regular care (Appendix Table F64). ^235^ Prompted voiding treatment increased the proportion of appropriate toileting to 60 percent compared to 17 percent after regular care (mean difference 1.7 percent, 95 percent CI 1.3; 2.2. ^233^ Individualized habit training for UI with verbal encouragement administered by nursing staff ^237^ significantly decreased the frequency of incontinence episodes by 19 percent in elderly residents without neurological diseases but not in memory-impaired residents. ^236^ Individualized prompted voiding and intensive endurance and pelvic floor muscle training significantly reduced the proportion of wet checks by nurses among total checks to 25 percent compared to 50 percent after usual care. ^234^ One RCT ^239^ examined the effects of rehabilitation based on the Functional Independence Measure scale on risk of UI in 34 patients with acute hemispheric stroke (Appendix Table F65). The number cured at discharge was four times larger after active rehabilitation compared to a conventional rehabilitation program (RR 4.1, 95 percent CI 1.5; 11.2) (Appendix Table F66).

One RCT of 32 women examined the effects of oral estrogen (0.63 mg) combined with progesterone (2.5 mg) and regular toileting assistance (prompted voiding) by trained research and did not report significance on rates of positive cough test or appropriate toileting rate. ^711^

#### Level of evidence

The evidence from nine RCTs ^233^ – ^237,^ ^708^ – ^711^ and one nonrandomized trial ^238^ was analyzed in relation to a variety of clinical outcomes in residents of nursing homes. One trial reported preplanned intention to treat analysis; four justified sample size; ^234,^ ^237,^ ^709,^ ^710^ allocation concealment was unclear in all open label trials. Baseline characteristics of the participants did not differ and confirmed adequacy of randomization in five trials. ^234^ – ^236,^ ^708,^ ^711^ Adherence of nursing staff to the protocol was not consistently analyzed, thus preventing valid comparisons of the treatment effects between the studies.

#### Summary

In conclusion, in contrast to numerous studies of the management of UI, only a few RCTs aimed at slowing progression in LTC settings. Individualized management programs that included prompted voiding, exercise, and positive feedback modestly improved the severity of symptoms. Active rehabilitation with self management of urinary symptoms resulted in continence in the majority of the patients after stroke. Fully powered RCTs would better estimate the effectiveness of individualized evidence-based conservative management programs. Cluster trials with randomization of nursing units, adequate allocation concealment, and preplanned intention to treat analysis are needed to provide valid results. The effectiveness of clinical interventions should be examined in subgroups of residents by cognitive and physical functioning, gender, and ethnicity. The effects of conservative management programs on the quality of life in these populations have not been investigated in RCTs. Staff participation in developing combined management protocols and adherence to protocols should be continuously measured as quality of care indicators in LTC facilities.

### Effects of Clinical Interventions on UI in Community Dwelling Adults

#### Implementation of evidence-based guidelines

(Appendix Table F67). National evidence-based guidelines were implemented in gynecology units in four district general hospitals across Scotland. Women were advised to follow the recommended appropriate protocol for 1 year. This intervention did not improve self-reported severity of UI and quality of life in women at 1 year of followup (Appendix Table F68). ^712^

#### Conservative management programs

Urinary continence service delivered by specially trained nurses included advice on diet and fluids, bladder training, and pelvic floor muscle awareness ^240^ in a large, well designed RCT of 3,746 incontinent men and women living in private households (Appendix Table F69). The proportion of cured patients was 1.5 times higher after the continence service (RR 1.5, 95 percent CI 1.3; 1.7) (Appendix Table F70). More patients reported improvement in UI 6 months after active treatment (RR 1.2, 95 percent CI 1.1; 1.3). The continence service also reduced progression of urgency to very strong or overwhelming by 30 percent (RR 0.7, 95 percent CI 0.7; 0.8). The complex rehabilitation program by nurse continence advisors and consulting urogynecologists including bladder training, gradual increase in fluid intake, pelvic floor muscle training, and transvaginal electrical stimulation resulted in urinary continence in 50 percent of women but with no statistically significant differences compared to usual care (Appendix Table F71). ^510^ Small significant improvement compared to usual care was detected in two quality of life measures, the Life Urogenital Distress Inventory (2.9 percent) and in the Short Form Urogenital Distress Inventory (16 percent) (Appendix Table F72). Community-based interventions, including education, bladder training, managing the urge to urinate, and pelvic floor muscle training, resulted in continence in 35 percent of women vs. 30 percent after usual care (RR 1.7, 95 percent CI 1; 2.9). ^241^ The majority of women reported more than 50 percent improvement in incontinence (RR 1.6, 95 percent CI 1.1; 2.2). ^241^ A continence management program implemented by nurse continence advisers with physician expertise included lifestyle modification sessions for 446 incontinent subjects. ^242^ Daily incontinence events were significantly reduced after active treatment with no changes in pad use (Appendix Table F73). ^242^ Educational programs about bladder health and recorded incontinence episodes in a voiding diary, in addition to listening to an audiotape daily, were examined in one RCT. ^713^ The combination of education and cognitive interventions significantly reduced the number of incontinent episodes (RR 1.7, 95 percent CI 1.1; 2.7) but did not improve perceived incontinence measured using the Urinary Incontinence and Frequency Comfort Questionnaire (Appendix Table F74).

#### Dietary and other lifestyle interventions in females

(Appendix Table F75). A standard low calorie liquid diet, increased physical activity to 60 minutes per day, training by a nutritionist, and exercise supervised by a physiologist or behavioral therapist improved stress UI in 92 percent, urge UI in 70 percent, and overall UI in 60 percent of participating women (RR of improvement in overall UI 3.5, 95 percent CI 1.3; 9.1) (Appendix Table F76). ^714^ Self-selected diet with low fat and low cholesterol foods and 25g of soy protein (Appendix Table F75) did not reduce the risk of stress and urge UI in women compared to a diet without soy (Appendix Table F77). ^715^ Increasing fluid intake by 500cc did not change the frequency of UI. ^716^ Restriction in caffeine intake in combination with increasing decaffeinated fluids significantly reduced the number of UI episodes by 87 percent but did not change urine loss in the pad weight test (Appendix Table F77). ^717^ A significant decrease in daytime episodes of involuntary urine loss after caffeine restriction was reported in another RCT. ^718^ A positive insignificant tendency to reduce the risk of stress UI was observed after the lifestyle interventions associated with the Diabetes Prevention Program RCT (RR 0.9, 95 percent CI 0.7; 1) (Appendix Table F78). ^245^

In adults, bladder training, fluid intake modification, and restricted caffeine intake to <100mg/day significantly decreased the number of voids by 6 percent, and daily urgency episodes by 21 percent, with random differences in daily leakage episodes compared to bladder training alone (Appendix Table F79). ^719^

#### Attributable to conservative management program events

We analyzed the number of avoided/excessive events per 1,000 treated from RCTs that reported significant effects of conservative combined interventions on UI (Table 44). Compared to usual care, continence service resulted in 90 additional cases of resolved UI (continent) 1,000 treated community dwelling adults (95 percent CI 49; 136). ^240^ A specially designed rehabilitation program resulted in 722 additional cases of resolved UI (continent) per 1,000 treated adults with stroke (95 percent CI 121; 235). ^239^ With continence service, UI was improved in an additional 100 subjects per 1,000 subjects treated (95 percent CI 56; 146), quality of life improved in 90 subjects (95 percent CI 52; 129), and satisfaction with present urinary symptoms in 110 (95 percent CI 66; 157). ^240^ A computerized quality management model for medical assessment and individualized prompted voiding would avoid progression of UI in 140 per 1,000 treated residents of nursing homes (95 percent CI 13; 216). ^238^

Table 44 Comparative effectiveness of combined conservative management interventions on UI (significant relative benefit of continence shown from individual studies)

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Williams, 2005 ^240^ | Continence service that included advice on diet and fluids; bladder training; pelvic floor awareness and lifestyle advice | Existing primary care including GP+ continence advisory services in the area. | 828/2958 | 150/788 | 28.00 | 19.00 | 1.47 | 11 | 90
N = 3,746 | | Outcome: continence | | | | | (1.26; 1.72) | (7; 20) | (49; 136)E
60% female | | Outcome: Satisfied with current urinary symptoms for rest of life | 1,893/2958 | 418/788 | 64.00 | 53.00 | 1.21 | 9 | 110
6 month followup | | | | | | | (1.12; 1.30) | (6; 15) | (66; 156)E
Wikander, 1998 ^239^ * | Specially designed rehabilitation program to increase patient independent management of incontinence | Conventional rehabilitation program | 20/21 | 3/13 | 95.24 | 23.08 | 4.13 | 1 | 722
N = 34 | | Outcome: continence | | | | | (1.52; 11.19) | (0; 8) | (121; 235)E
56% female | | Outcome: Number discharged to a nursing home due to incontinence | 2/21 | 8/13 | 9.52 | 61.54 | 0.15 | 2 | 520
3 month followup | | | | | | | (0.04; 0.62) | (2; 4) | (234; 592)A
Schnelle, 1995 ^238^ * | After gradual implementation of computerized quality management model for medical assessment and individualized prompted voiding protocols of incontinence | Before implementation of quality management model. | 14/85 | 26/85 | 17.00 | 31.00 | 0.54 | 7 | 140
N = 85 | | Outcome: proportion of wet residents | | | | | (0.30; 0.96) | (5; 77) | (216; 13)A
6 month followup

* Long-term care settings;

Bold - significant differences in outcomes at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement in incontinence) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated, A - number of avoided events per 1,000 treated

#### Primary prevention of female UI related to pregnancy and birth

was examined in eight large RCTs with more than 100 women ^246^ – ^253^ (two studies were published twice with different duration of followup ^246,^ ^251^ ) and one smaller trial ^254^ (Appendix Table F80). Conservative advice about self-administered pelvic floor muscle training at 5, 7, and 9 months after delivery supplemented with bladder training did not change the risk of stress UI and tended to decrease the risk of severe UI at 12 months postpartum (Appendix Table F81). ^251,^ ^252^ No improvement was seen in women with severe (>1 week) UI at baseline. ^252^ Self-rated severity was significantly reduced by 87 percent (95 percent CI -93.0; -81.1) compared to usual postpartum care (Appendix Table F82). Pelvic floor muscle training that occurred within 48 hours of delivery reduced the risk of self-reported UI 3 months postpartum (RR 0.8, 95 percent CI 0.7; 1.0), ^246^ but the effect was attenuated at 12 months ^248^ (Appendix Table F83). Pelvic floor muscle training that started 1 month before delivery reduced the risk of postpartum stress incontinence (RR 0.6, 95 percent CI 0.4; 0.9). ^247^ Standardized instruction in pelvic floor muscle training started before delivery did not decrease the risk of stress UI compared to regular care in a small RCT without justified sample size. ^254^ In addition to visits and phone calls by community midwives, reminders, feedback to self measure squeeze pressure, and voiding diary, pelvic floor muscle training did not reduce the risk of incontinence 3 months postpartum in an RCT of 1,800 participants. ^253^ The combination of pelvic floor muscle training with biofeedback and intravaginal electrostimulation resulted in a continence rate of 19 percent vs. 2 percent after usual care (RR of continence 11.0, 95 percent CI 1.5; 82.8) with no significant improvement in urodynamic outcomes (Appendix Table F84). ^249^ Self-administered perineal massage daily from the 34^th^ or 35^th^ week of pregnancy until delivery did not improve the continence rate in a large sample of pregnant women with (n = 493) and without (n = 1,034) a previous vaginal birth. ^250^

We estimated that assessment of UI by nurses with conservative advice on pelvic floor muscle training supplemented with bladder training could avoid 121 cases of UI (95 percent CI 7; 152) and 59 cases of severe incontinence (95 percent CI 5; 99) among 1,000 treated (Table 45). ^251^

Table 45 Comparative effectiveness of combined conservative management intervention on female UI related to pregnancy and birth (primary prevention)

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Glazener, 2001 ^251^ | Assessment by nurses of urinary incontinence with conservative advice on pelvic floor exercises supplemented with bladder training | Outcome: severe incontinence (at least once a week) at 12 months postpartum | 55/371 | 78/376 | 14.82 | 20.74 | 0.71 | 17 | 59
N = 747 | | | | | | | (0.52; 0.98) | (10; 220) | (5; 99)A
100% female | | Outcome: severe incontinence in women with high initial severity (>1/week) | 43/371 | 65/376 | 11.59 | 17.29 | 0.67 | 18 | 57
12 month followup | | | | | | | (0.47; 0.96) | (11; 140) | (7; 92)A

Bold - significant differences in outcomes at 95% confidence level;

A - number of avoided events per 1,000 treated.

Number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

#### Pelvic floor muscle training for secondary prevention of UI in community dwelling females

Complex behavioral modification programs, including pelvic floor muscle training, bladder training, and individualized testing of knowledge, adherence, and skills, were implemented in 359 postmenopausal, continent women 55 years and older (Appendix Table F85). ^243,^ ^244^ Behavioral modification did not cure UI at 1 year of followup, although the improvement rate in urinary symptoms was 36 percent higher after intervention vs. standard care (RR 1.4, 95 percent CI 1.1; 1.7). ^243^

The effects of behavioral interventions on UI in females were examined in 21 RCTs. ^267^ – ^287^ The effects of pelvic floor muscle training on stress UI in women were examined in 18 RCTs (Appendix Table F86). ^288^ – ^290,^ ^292,^ ^299,^ ^316,^ ^720^ – ^731^ The rates of cure of UI, improvement or progression of UI, continuous severity measures, and urodynamic outcomes after active treatments were compared to usual care or active controls.

##### Outcome - continence

Several RCTs reported subjective cure of UI ^275,^ ^290,^ ^299^ or objective continence during a stress test or urodynamic exam ^268,^ ^299,^ ^721,^ ^731^ (Appendix Table F87). Curative behavioral interventions included pelvic floor muscle training, bladder training, and electromyography biofeedback. The rate of continence after treatment varied from less than 10 percent ^253,^ ^299,^ ^730^ to more than 75 percent. ^288^ Smaller trials tended to report greater continence rates. ^275,^ ^288,^ ^731^ The largest relative benefit on continence was observed after electromyography (EMG)-assisted biofeedback with pelvic floor muscle training compared to usual care in postmenopausal women with stress UI taking hormone replacement therapy (RR 17.3, 95 percent CI 1.1; 261.7). ^288^ Pelvic floor muscle training in groups with skilled physical therapists increased subjective cure from stress UI (RR 15.4, 95 percent CI 2.2; 110.3). ^299^ Women with stress UI experienced objective cure after this treatment six times more often compared to untreated controls (RR 6.1, 95 percent CI 1.5; 25.1). ^299^ Older women with sphincteric incompetence reported cure from stress UI eight times more often compared to regular care (RR 8.8, 95 percent CI 1.2; 66). ^289^ Individualized behavioral intervention with pelvic floor muscle training for stress UI or bladder training for urge UI resulted in continence in 19 percent of women with substantial relative benefit compared to regular care (RR 10.4, 95 percent CI 14; 78.3). ^280^ The trials with active controls reported comparable rates of continence without significant relative benefit on urinary continence. ^268,^ ^269,^ ^271,^ ^274^ – ^276,^ ^721,^ ^727,^ ^730,^ ^731^

##### Outcome - Improvement in UI in community dwelling females

The majority of RCTs that examined behavioral interventions reported improvement in self-reported severity of UI and quality of life (Appendix Table F88). ^243,^ ^268,^ ^269,^ ^278^ – ^281,^ ^283,^ ^286,^ ^288,^ ^289,^ ^292,^ ^299,^ ^724,^ ^725,^ ^727,^ ^730^ The rates of improvement varied from 20 percent in improved pad test after pelvic floor muscle training with intravaginal EMG biofeedback ^288^ to 94 percent in improved stress test after pelvic floor muscle training. ^725^

Individual pelvic floor muscle training and bladder training with delayed voiding resulted in self-reported improvement in 94 percent of women. ^286^ Behavioral training that included biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self monitoring with bladder diaries reduced weekly incontinence episodes by more than 50 percent in 86 percent of women ages 40–78 years with all types of UI. ^268^ The same consistent effect was observed after bladder training with positive reinforcement in older women with clinical and urodynamic UI >1 leakage/week. ^281^ Significant improvement in restriction of daily activities attributable to UI was reported after pelvic floor muscle training (RR 12.5, 95 percent CI 3.2; 48.6). ^292^ Two small RCTs of pelvic floor muscle training ^292^ and exercises with biofeedback ^724^ reported substantial relative benefits when no women reported improvement in UI after usual care. Other RCTs showed more than 25 percent relative benefit after biofeedback-assisted behavioral training (RR 1.6, 95 percent CI 1.1; 2.3 ^279^ or after bladder training (RR 3.1, 95 percent CI 2.0; 4.9; ^281^ RR 3.4, 95 percent CI 1.9; 6.1 ^278^ ) compared to usual care. Women reported more than 50 percent reduction in UI episodes after bladder training (RR 3.1, 95 percent CI 2.0; 4.9) compared to usual care. ^281^ Two RCTs reported significantly larger benefits of behavioral training compared to self-administered behavioral changes using a booklet. ^268,^ ^283^

##### Outcome - Progression of UI in community dwelling females

Severity of UI was estimated with self-reported frequency of leakage episodes, pad utilization, and bothersomeness of UI. Community-based intervention that included bladder training and performing pelvic floor muscle training among elderly women resulted in 30 percent reduction in pad use for UI (RR 0.7, 95 percent CI 0.6; 0.9). (Appendix Table F89) ^291^ Intensive pelvic floor muscle training with 8–12 maximum contractions in 3 series/day and 45 minutes/week group sessions among women with clinically and urodynamically proven stress UI reduced the prevalence of UI with sexual intercourse by 80 percent (10.5 percent vs. 41.7 percent RR 0.2, 95 percent CI 0.2; 0.8). ^720^ The adverse impact on quality of life was reduced by 30 percent (RR 0.7, 95 percent CI 0.6; 0.9) ^291^ to 40 percent (RR 0.6, 95 percent CI 0.4; 0.9) ^720^ The relative benefit of behavioral interventions was demonstrated when compared to usual care but not to active controls.

#### Clinical interventions for primary prevention of UI in community dwelling males

##### Outcome - Continence

The behavioral interventions on UI in males with prostate diseases were examined in 12 RCTs (Appendix Table F90). ^255^ – ^266^ Pelvic floor rehabilitation programs resulted in continence rates from 77 percent ^255^ to 99 percent ^257^ (Appendix Table F91). The highest continence rate was reported in a large well designed RCT of early pelvic floor rehabilitation in patients who had radical retropubic prostatectomy for clinical stage T1 or T2 prostate cancer. ^257^ The majority of patients (99 percent) reported continence after the intervention that included verbal explanations, palpation, and Kegel exercises with a small significant relative benefit compared to usual care (RR 1.1, 95 percent CI 1.1; 1.2). ^257^ The relative effect in the same RCT was larger when continence status was measured with a scale specific for UI (RR 1.3, 95 percent CI 1.2; 1.5). ^257^ Continence rates in the control groups were more than 60 percent across all RCTs with no statistically significant differences compared to active treatments (Figure 29).

Figure 29. Relative benefit of urinary continence after active treatment compared to usual care in males with urological diseases (efficacy RCTs, primary prevention)

PFMT pelvic floor muscle training; PFMT + BFB pelvic floor muscle training with biofeedback; Stimulation = electrical stimulation

* incontinence was measured using International Continence Society male questionnaire

##### Outcome - UI in community dwelling males

The effects of behavioral interventions on severity of UI were inconsistent in direction and size compared to usual care (Appendix Table F92). Few RCTs reported significant benefits of behavioral treatments to reduce the risk of UI. The rate of self-reported UI was 70 percent less after verbal instruction and feedback on contractions of pelvic floor muscles in 63 patients with bladder outflow obstruction and diagnosis of symptomatic benign prostatic hyperplasia who undergo transurethral prostatectomy (RR 0.3, 95 percent CI 0.1; 0.9). ^263^ Pelvic floor muscle training, including a strong post-void “squeeze out” pelvic floor muscle contraction, biofeedback, and suggestions to change lifestyle, significantly reduced post micturition dribble and urine loss in men with erectile dysfunction. ^266^ One large trial showed a substantial benefit of a complex floor rehabilitation program including patient education, assessment of pelvic floor muscles strength, and visualization of Kegel pelvic floor muscle training compared to regular care with reduction in severity and pad utilization (RR of using two pads/day 0.1, 95 percent CI 0; 0.7). ^257^

#### Behavioral clinical interventions for secondary prevention of urinary continence in adults

The effects of behavioral interventions in males and females were examined in four RCTs (Appendix Table F93). ^43,^ ^732^ – ^734^ One large RCT of pelvic floor muscle training and bladder retraining supervised by non-specialist nurses in 561 adults 35 years and older with regular UI reported a significant increase in cure (RR 15.5, 95 percent CI 2.1; 112.5) and improvement of UI (RR 12.6, 95 percent CI 6; 26.2) (Appendix Table F94). ^43^

### Effects of Behavioral Interventions on Severity of UI and Quality of Life

#### Surrogate outcomes

##### Subjective measures of severity of UI and quality of life in females (continuous surrogate variables)

The authors measured severity of UI using self-reported numbers of episodes of UI per time period. The effects of behavioral interventions on quality of life were estimated from questionnaires and scales expressing the effects as mean differences between active and control treatments (Appendix Table F95). We calculated the effect size as the percent change in outcome variables compared to the control group. Overall, behavioral interventions resulted in small random changes in outcomes compared to control groups. No consistent benefit was seen across RCTs on severity or quality of life. The largest differences were reported in one RCT that showed a reduction in the number of daily leakages after pelvic floor muscle training in groups supervised with skilled physical therapists (mean difference -0.7, 95 percent CI -1.2;-0.2). ^299^ The same RCT reported a significant increase in the Social Activity Index (mean differences 0.6, 95 percent CI 0.1; 1.1). ^299^ The results were inconsistent within trials. Pelvic floor muscle training improved self-reported UI measured with the Visual Analog Scale of UI but also increased the number of stress incontinence episodes. ^288^ Behavioral interventions reduced the number of incontinence episodes by 0.5–1 per day. ^282,^ ^292^ The effect on quality of life was also small with less than 1 percent differences in scores on the Incontinence Impact Questionnaire (mean difference -0.5, 95 percent CI -0.9;-0.2). ^284^

##### Objective measures of severity of UI in females (pad test, urodynamic cystometry, and perineometry)

Few behavioral interventions improved objective severity compared to either regular care or other treatments (Appendix Table F96). Behavioral management for continence reduced urine loss per 24 hours in the pad weight test compared to regular care (mean difference -0.5, 95 percent CI -0.8; -0.2). ^282^ The same benefit (approximately 1 percent difference compared to the control group) was reported after bladder training. ^281^ The largest significant differences (44 percent compared to usual care) in the 1 hour pad test was shown after pelvic floor muscle training with digital biofeedback (mean difference -12.3, 95 percent CI -15.6; -9). ^288^ Several RCTs of behavioral interventions reported small significant reductions in vaginal pressure ^274^ and significant increase in peak pressure ^285,^ ^729^ and pelvic floor muscle training. ^288,^ ^725^

One RCT examined the effects of contracting the pelvic floor muscles before and during a cough (Knack Maneuver) in 27 women with self-reported stress UI and did not show significant improvement in urine leakage during the cough paper towel test. ^722^

##### Subjective measures of severity of UI in males

Self-reported urinary symptoms and pad use did not change after active treatments compared to regular care (Appendix Table F97). One RCT reported increased urine loss in the pad weight test after intensive pelvic floor muscle training conducted by a physiotherapist (Appendix Table F98).

##### Subjective measures of severity of UI in adults

The frequency of UI in adults after behavioral interventions was reported in two RCTs (Appendix Table F99). ^732,^ ^733^ The larger RCT showed reduced UI episodes/day (mean difference -0.6, 95 percent CI -1.0; -0.2) after biofeedback-assisted pelvic floor muscle training. ^732^

#### Pooled estimates of behavioral interventions on urinary continence in adults

The differences in populations and treatments, including difference in training regimes and frequency, made a pooled analysis questionable. We compared the relative benefit of urinary continence after behavioral interventions to usual care (Table 46). Pelvic floor muscle training, biofeedback assisted pelvic floor muscle training, and a combination of pelvic floor muscle training with bladder training showed an inconsistent relative benefit across studies. Pooled relative benefits of pelvic floor muscle training in females (RR 7.1, 95 percent CI 2.8; 18) ^280,^ ^288,^ ^289,^ ^299^ and pelvic floor muscle training combined with biofeedback (RR 11.2, 95 percent CI 2.2; 56.4) ^288,^ ^289^ were sensitive to one small RCT ^288^ with 2 month followup (Figure 30). Pelvic floor muscle training combined with bladder training increased continence by 175 percent compared to usual care (pooled RR 1.8, 95 percent CI 1.1; 2.9). ^241,^ ^243,^ ^280,^ ^290^

Table 46 Relative benefit of urinary continence after behavioral interventions in adults compared to regular care (random effects models, secondary prevention)

Author | Relative Risk (95% CI)
Sample; Followup
Pelvic Floor Muscle Training
Parekh, 2003 ^265^ | 1.07 (0.79; 1.44)
N = 38; 0% female; 12 month followup
O'Brien, 1991 ^43^ | 15.49 (2.13; 112.49)
N = 561; 76% female; 3 month followup
Aksac, 2003 ^288^ | 16.24 (1.07; 246.51)
N = 50; 100% female; 2 month followup
Burns, 1993 ^289^ | 6.35 (0.82; 49.32)
N = 135; 100% female; 39 month followup
Lagro-Janssen, 1992 ^280^ | 7.00 (0.91; 53.78)
N = 66; 100% female; 3 month followup
Sleep, 1987 ^253^ | 0.96 (0.53; 1.72)
N = 1,800; 100% female; 3 month followup
Kim, 2001 ^290^ | 3.19 (0.75; 13.55)
N = 33; 100% female; 3 month followup
Biofeedback-assisted Pelvic Floor Muscle Training
Filocamo, 2005 ^257^ | 1.12 (1.05; 1.19)
N = 300; 0% female; 12 month followup
Mathewson-Chapman, 1997 ^259^ | 0.97 (0.87; 1.07)
N = 53; 0% female; 3 month followup
Franke, 2000 ^264^ | 1.00 (0.76; 1.32)
N = 30; 0% female; 6 month followup
Williams, 2005 ^240^ | 1.47 (1.26; 1.72)
N = 3,746; 60% female; 6 month followup
Meyer, 2001 ^249^ | 10.98 (1.46; 82.8)
N = 107; 100% female; 10 month followup
Aksac, 2003 ^288^ | 17.29 (1.14; 261.69)
N = 50; 100% female; 2 month followup
Burns, 1993 ^289^ | 8.78 (1.17; 66.04)
N = 135; 100% female; 6 month followup
Pelvic Floor Muscle Training and Bladder Training
Diokno, 2004 ^243^ | 1.32 (0.98; 1.78)
N = 359; 100% female; 12 month followup
Lagro-Janssen, 1991 ^292^ | 10.37 (1.37; 78.28)
N = 106; 100% female; 3 month followup
McFall, 2000 ^241^ | 1.69 (0.97; 2.93)
N = 145; 100% female; 3 month followup

Figure 30. Relative benefit of urinary continence after active treatment compared to usual care in females (efficacy RCTs, secondary prevention)

PFMT pelvic floor muscle training; BT bladder training; PFMT+BT pelvic floor muscle training combined with bladder training; PFMT+ EMG BFB pelvic floor muscle training with electromyography biofeedback; * continence was defined as negative pad test

The majority of RCTs demonstrated significant improvement in UI after pelvic floor muscle training compared to regular care. An improvement was shown eight times more often after pelvic floor muscle training (RR 8.1, 95 percent CI 2.3; 28.4), twice as frequently after biofeedback assisted pelvic floor muscle training (RR 1.9, 95 percent CI 1.0; 3.5), and 2.5 times more often after pelvic floor muscle training and bladder training (RR 2.5, 95 percent CI 1.4; 4.6) (Figure 31).

Figure 31. Relative benefit of improvement in UI after active treatment compared to usual care (pooled results RCTs, random effects model)

PFMT pelvic floor muscle training; PFMT + BFB pelvic floor muscle training with biofeedback; PFMT + BT - pelvic floor muscle training with bladder training

#### Attributable benefits of behavioral interventions

Few RCTs showed significant relative benefit of behavioral interventions on urinary continence (Table 47). The number of avoided stress UI cases per 1,000 varied from 170 ^249^ to 749 ^288^ when treated with behavioral interventions. The relative benefits on total UI was smaller. ^43,^ ^257^ Ignoring different definitions of improvements and possible attenuation of the improvement over time, weight reduction would result in improved stress UI in 990 adults per 1,000 treated (Table 48). ^714^

Table 47 Comparative effectiveness of behavioral interventions on urinary continence in adults from the community (significant results from individual RCTs)

Author | Active Treatment | Control Treatment | Number Continent After Active Treatment/ Number Randomized | Number Continent After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events per 1,000 treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Continence in Patients with Stress UI
Meyer, 2001 ^249^ * | 12 sessions of PFMT with 20 minutes of biofeedback and 15 minutes of electro stimulation | Usual care | 10/51 | 1/56 | 19.00 | 2.00 | 10.98 | 6 | 170
N = 107 | | | | | | | (1.46; 82.80) | (1; 110) | (9; 1,636)E
100% female
10 month followup
Bo, 2005 ^275^ | PFMT with 8–12 max contractions for 6–8 seconds 3 series/day under the supervision of physical therapist | Home exercise groups | 13/21 | 4/26 | 60.00 | 17.00 | 4.02 | 2 | 430
N = 47 | | | | | | | (1.54; 10.53) | (1; 11) | (91; 1,620)E
100% female
Acute
Aksac, 2003 ^288^ | PFMT (contractions for 10 seconds and relaxation for 20 seconds, 10 times/ session, 3 sessions/day) BFB digital palpation at home | Usual care | 15/20 | 0/10 | 75.00 | 0 | 16.24 | 1 | 749 E
N = 50 | | | | | | | (1.07; 246.51)
100% female | The same PFMT+ EMG BFB via vaginal probe | | 16/20 | 0/10 | 80.00 | 0 | 17.29 | 1 | 799E
2 month followup | | | | | | | (1.14; 261.69)
Burns, 1993 ^289^ | PFMT (contraction for 10 seconds and relaxations for 10 seconds 10 times in each weekly session)+ vaginal EMG BFB | Usual care | 9 | 1 | 23.00 | 3.00 | 8.78 | 5 | 200
N = 135 | | | | | | | (1.17; 66.04) | (1;201) | (5; 1,951)E
100% female
6 month followup
Bo, 1999 ^299^ | PFMT with 8–12 contractions 3 times/day, in groups with skilled physical therapists 1/week | Untreated control group offered the use of continence guard. Objective cure as <2g leakage on the pad test with standardized bladder volume | 11/29 | 2/32 | 37.93 | 6.25 | 6.07 | 3 | 317
N = 122 | | | | | | | (1.47; 25.12) | (1; 34) | (29; 1,507)E
100% female | | Subjective cure (number of women stating that the condition was “unproblematic” after the treatment) | 14/29 | 1/32 | 48.28 | 3.13 | 15.45 | 2 | 452
6 month followup | | | | | | | (2.16; 110.28) | (0; 27) | (36; 3,415)E
Continence in Patients with Any UI
Janssen, 2001 ^286^ | Individual PFMT 5 times/day and bladder training with delay voiding, training with 11 30-minute sessions. | Group PFMT 5 times/day and bladder training with delay voiding, training with 9 2-hour sessions | 28/126 | 57/404 | 22.00 | 14.00 | 1.58 | 13 | 80
N = 530 | | | | | | | (1.05; 2.36) | (5; 143) | (7; 191)E
100% female
12 month followup
O'Brien, 1991 ^43^ | Four sessions of PFMT and BT supervised by non-specialist nurse | Usual care | 32/378 | 1/183 | 8.47 | 0.55 | 15.49 | 13 | 79
N = 561 | | | | | | | (2.13; 112.49) | (2; 161) | (6; 609)E
76% female
3 month followup
Lagro-Janssen, 1992 ^280^ | PFMT alone (stress) or BT (urge) or its combination (mixed) | Usual care | 10/54 | 1/56 | 18.52 | 1.79 | 10.37 | 6 | 167
N = 106 | | | | | | | (1.37; 78.28) | (1; 150) | (7; 1,380)E
100% female
3 month followup
Filocamo, 2005 ^257^ * | Early pelvic floor rehabilitation program with verbal explanation, PFMT +BFB (digital anal control, visualization: 3 sets of 10 contractions for 5 seconds and 10 seconds of muscular relaxation | No formal training on PFMT Outcome: Self-reported urinary continence | 148/150 | 132/150 | 98.7 | 88.00 | 1.12 | 9 | 107
N = 300 | | | | | | | (1.05; 1.19) | (6; 21) | (47; 170)E
0% female | | Outcome: International Continence Society (ICS)-male questionnaire: completely dry | 134/150 | 101/150 | 89.33 | 67.33 | 1.33 | 5 | 220
12 month followup | | | | | | | (1.17; 1.50) | (3; 9) | (115; 338)E
Van Kampen, 2000 ^261^ | Pelvic-floor re-education program with PFMT+BFB for as long as patients were incontinent. | Placebo electrotherapy (a false interferential current) via four skin electrodes | 44/50 | 36/52 | 88.00 | 70.00 | 1.27 | 6 | 180
N = 102 | | | | | | | (1.03; 1.57) | (3; 44) | (23; 396)E
0% female
12 month followup

* Sampling of continent adults at baseline (primary prevention);

PFMT - pelvic floor muscle training, BFB - biofeedback; BT - bladder training;

Bold - significant differences in outcomes at 95% confidence level;

E - number of excessive events per 1,000 treated;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

Table 48 Comparative effectiveness of behavioral interventions to improve UI in adults (significant results from individual RCTs)

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events per 1,000 Treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Improvement in Stress UI
Subak, 2005 ^714^ | Weight reduction intervention | Delayed weight reduction intervention | 22/24 | 0/24 | 92.00 | 0 | 45.00 | 1 | 919E
N = 48 | | | | | | | (2.89; 701.85)
100% female
3 month followup
Burns, 1993 ^289^ | PFMT (contraction for 10 seconds and relaxations for 10 seconds 10 times in each weekly session)+vaginal EMG BFB | Usual care | 24/40 | 2/39 | 61.00 | 6.00 | 11.70 | 2 | 550
N = 135 | | | | | | | (2.96; 46.20) | (-8; 0) | (118; 2,712)E
100% female | PFMT with 4 sets of 20 increasing by 10/set until maximum 200 sets/day | | 23/40 | 2/39 | 54.00 | 6.00 | 10.43 | 2 | 480
6 month followup | | | | | | | (2.63; 41.39) | (0; 10) | (98; 2,424)E
Wells, 1991 ^725^ | PFMT with contractions for 10 seconds and relaxation for 10 seconds 90–160 times/day | Phenylpropanolamine hydrochloride in a dose of 50mg/ day, increasing to 50mg 2 times/day | 17/82 | 29/75 | 21.00 | 39.00 | 0.54 | 6 | 180
N = 157 | | | | | | | (0.32; 0.89) | (4; 24) | (264; 42)A
100% female
6 month followup
Bo, 1999 ^299^ | PFMT with 8–12 contractions 3 times/day in groups with skilled physical therapists 1/week | Untreated control group offered the use of a continence guard | 12/29 | 1/32 | 41.38 | 3.13 | 13.24 | 3 | 383
N = 122 | | | | | | | (1.83; 95.63) | (0; 38) | (26; 2,957)E
100% female
6 month followup
Lagro-Janssen, 1999 ^292^ | Instructions in PFMT 5–10 sessions of 10 pelvic muscle contractions for 6 seconds each day | No therapy. Outcome: improvement in urinary incontinence | 28/33 | 0/33 | 85.00 | 0 | 57.00 | 1 | 849 E
N = 66 | | | | | | | (3.62; 896.38)
100% female | | Outcome: improvement in psychological impact of urinary incontinence | 23/33 | 0/33 | 70.00 | 0 | 47.00 | 1 | 699E
3 month followup | | | | | | | (2.97; 742.97)
| | Outcome: improvement in restriction of activities | 25/33 | 2/33 | 75.00 | 6.00 | 12.50 | 1 (0; 8) | 690
| | | | | | | (3.22; 48.56) | | (133; 2,854)E
Improvement in Any UI
Janssen, 2001 ^286^ | Individual PFMT 5 times/day and bladder training with delay voiding, training with 11 30-minute sessions | Group PFMT 5 times/day and bladder training with delay voiding, training with 9 2-hour sessions | 118/126 | 347/404 | 94.00 | 86.00 | 1.09 | 13 | 80
N = 530 | | | | | | | (1.03; 1.16) | (7; 447) | (23; 136)E
100% female
12 month followup
Subak, 2005 ^714^ | Weight reduction intervention | Delayed weight reduction intervention | 14/24 | 4/24 | 60.00 | 15.00 | 3.50 | 2 | 450
N = 48 | | | | | | | (1.35; 9.11) | (19; 1) | (52; 1,216)E
100% female
3 month followup
Diokno, 2004 ^243^ * | Behavioral modification program: PFMT+BT | Usual care | 92/164 | 80/195 | 56.00 | 41.00 | 1.37 | 7 | 150
N = 359 | | | | | | | (1.10; 1.70) | (3; 24) | (42; 286)E
100% female
12 month followup
Goode, 2003 ^268^ | Behavioral training (PFMT+BFB, home exercises, bladder control strategies, and self-monitoring with bladder diaries) and pelvic floor electrical stimulation | Self-administered behavioral training administered with a self-help booklet | 58/67 | 38/67 | 86.00 | 57.00 | 1.53 | 3 | 290
N = 200 | | | | | | | (1.21; 1.92) | (2; 8) | (122; 524)E
100% female
2 month followup
O'Brien, 1991 ^43^ | Four sessions of PFMT+BT supervised by non-specialist nurse | Usual care | 182/378 | 7/183 | 48.15 | 3.83 | 12.59 | 2 | 443
N = 561 | | | | | | | (6.04; 26.22) | (1; 5) | (193; 965)E
76% female
3 month followup
Subak, 2002 ^278^ | 6 weekly 20-minute group instructional sessions on BT by nurse educators and followed individualized voiding schedules | Usual care | 39/77 | 11/75 | 50.00 | 15.00 | 3.41 | 3 | 350
N = 152 | | | | | | | (1.89; 6.15) | (1; 7) | (134; 772)E
100% female
1.5 month followup
Lagro-Janssen, 1992 ^280^ | PFMT alone (stress) or BT (urge) or its combination (mixed) | Usual care | 40/54 | 2/56 | 74.00 | 3.00 | 20.74 | 1 | 710
N = 106 | | | | | | | (5.27; 81.63) | (0; 8) | (128; 2,419)E
100% female
3 month followup
McFall, 2000 ^241^ | Community-based intervention: BT, managing the urge to urinate, and PFMT | Usual care | 44/72 | 28/73 | 61.00 | 38.00 | 1.59 | 4 | 230
N = 145 | | | | | | | (1.13; 2.25) | (2; 20) | (49; 474)E
100% female
3 month followup
Fantl, 1991 ^281^ | BT using 6 weekly visits included patient education; voiding schedule to have micturition from every 30–60 minutes to every 2.5–3 hours; and positive reinforcement. | Usual care | 49/65 | 16/66 | 75.00 | 24.00 | 3.11 | 2 | 510
N = 131 | | | | | | | (1.99; 4.87) | (1; 4) | (237; 929)E
100% female
1.5 month followup
Burgio, 2002 ^283^ | BFB+PFMT+ behavioral training implemented by nurse practitioners | Self-administered behavioral treatment using a self-help booklet to advice PFMT and bladder control | 33/73 | 20/75 | 45.21 | 26.67 | 1.70 | 5 | 185
N = 222 | | | | | | | (1.08; 2.66) | (2; 48) | (21; 444)E
100% female | 4 visits of behavioral training without BFB (verbal feedback based on vaginal palpation). PFMT with 10 second contractions and 10 second relation for 45 minutes/day | | 36/74 | 20/75 | 48.65 | 26.67 | 1.82 | 5 | 220
2 month followup | | | | | | | (1.17; 2.84) | (2; 22) | (46; 490)E
Hu, 1990 ^710^ | Behavioral therapy program in nursing homes implemented by the project-trained NRAs. | Usual care | 19/72 | 6/71 | 26.00 | 8.00 | 3.12 | 6 | 180
N = 143 | | | | | | | (1.32; 7.36) | (2; 38) | (26; 509)E
100% female
3 month followup
Dorey, 2004 ^266^ | PFMT including a strong post-void “squeeze out” pelvic floor muscle contraction, BFB, and suggestions for lifestyle changes. | Advice on lifestyle changes | 14/28 | 1/27 | 50.00 | 3.70 | 13.50 | 2 | 463
N = 55 | | | | | | | (1.90; 95.71) | (0; 30) | (33; 3,508)E
0% female
3 month followup
Burns, 1990 ^724^ | Kegel PFMT 4 times/day | Usual care | 21/38 | 0/40 | 54.00 | 0 | 45.21 | 2 | 539 E
N = 128 | | | | | | | (2.83; 720.96)
100% female
6 month followup
Goode, 2003 ^268^ | Behavioral training (BFB+PFMT, home exercises, bladder control strategies, and self-monitoring with bladder diaries) | Self-administered behavioral training administered with a self-help booklet | 53/66 | 38/67 | 80.00 | 57.00 | 1.42 | 4 | 230
N = 200 | | | | | | | (1.11; 1.80) | (2; 16) | (64; 457)E
100% female
2 month followup
Improvement in Urge UI
Subak, 2005 ^714^ | Weight reduction intervention | Delayed weight reduction intervention | 17/24 | 3/24 | 70.00 | 11.00 | 5.67 | 2 | 590
N = 48 | | | | | | | (1.91; 16.84) | (1; 10) | (100; 1,742)E
100% female
3 month followup
Goode, 2002 ^279^ | Four sessions (over 8 weeks) of biofeedback-assisted behavioral training by nurse practitioners | Usual care | 27/35 | 19/37 | 82.30 | 51.50 | 1.59 | 3 | 308
N = 70 | | | | | | | (1.12; 2.27) | (2; 16) | (62; 652)E
100% female
2 month followup

* Sampling of continent adults at baseline, interventions to reduce the risk of incontinence

Bold - significant differences in outcomes at 95% confidence level;

PFMT - pelvic floor muscle training, BFB - biofeedback; BT - bladder training;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated.

Intensive lifestyle changes would avoid 54 cases of stress UI per 1,000 treated (Table 49). ^245^ Pelvic floor muscle training and strategies to improve adherence among pregnant women would avoid 390 cases of UI per 1,000 treated (Table 50). ^246^

Table 49 Comparative effectiveness of behavioral interventions on UI in adults

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Outcome - Stress UI
Brown, 2006 ^245^ * | Intensive lifestyle therapy to lose and maintain at least 7% of initial body weight through a low-fat diet and to engage in moderate-intensity physical activity for at least 150 minutes each week | Placebo twice daily | 206/659 | 242/660 | 31.30 | 36.70 | 0.85 | 19 | 54
N = 1,957 | | | | | | | (0.73; 0.99) | (10; 329) | (3; 98)A
100% female
34.8 month followup
Primary prevention
Reilly, 2002 ^247^ * | Supervised by physiotherapist PFMT 1/month before delivery | Verbal advice on PFMT | 23/120 | 36/110 | 19.20 | 32.70 | 0.59 | 7 | 135
N = 268 | | | | | | | (0.37; 0.92) | (5; 40) | (25; 205 25)A
100% female
5 month followup
Primary prevention
Bo, 2000 ^720^ | PFMT with 8–12 maximum contractions in 3 series/day and 45 minute/week group sessions | Untreated control group | 3/29 | 13/30 | 10.50 | 41.70 | 0.24 | 3 | 312
N = 59 | | | | | | | (0.08; 0.75) | (3; 10) | (385; 104)A
100% female
6 month followup
Outcome - Any UI
Chiarelli, 2002 ^246^ * | Training in PFMT and incorporated strategies to improve adherence | Usual postpartum care | 115/370 | 134/350 | 31.00 | 38.40 | 0.81 | 14 | 74
N = 720 | | | | | | | (0.66; 0.99) | (8; 390) | (3; 129)A
100% female
3 month followup
Primary prevention
Filocamo, 2005 ^257^ * | Early pelvic floor rehabilitation program with verbal explanations, Kegel PFMT: 3 sets of 10 contractions for 5 seconds and 10 seconds of muscular relaxation under digital BFB | No formal training Outcome: occasional leakage in International Continence Society (ICS) - male questionnaire | 14/150 | 29/150 | 9.33 | 19.33 | 0.48 | 10 | 100
N = 300 | | | | | | | (0.27; 0.88) | (7; 42) | (142; 24)A
0% female | | Outcome ICS - male questionnaire: 2 pads/day | 1/150 | 11/150 | 0.67 | 7.33 | 0.09 | 15 | 67
12 month followup | | | | | | | (0.01; 0.70) | (14; 45) | (22; 72)A
Primary prevention | | Outcome: self-reported urinary incontinence | 2/150 | 18/150 | 1.33 | 12.00 | 0.11 | 9 | 107
| | | | | | | (0.03; 0.47) | (9; 16) | (64; 117)A
Porru, 2001 ^263^ * | Verbal instruction, BFB+PFMT, and verbal reinforcement to teach selective contractions of anal sphincter muscles and relaxation of abdominal muscles 45 times/day | Standard care without instruction on PFMT | 4/30 | 12/28 | 13.33 | 42.86 | 0.31 | 3 | 295
N = 58 | | | | | | | (0.11; 0.85) | (3; 16) | (63; 380)A
0% female
1 month followup
Primary prevention

* Sampling of continent adults at baseline;

Bold - significant differences in outcomes at 95% confidence level;

PFMT - pelvic floor muscle training, BFB - biofeedback; BT - bladder training;

A - number of avoided events per 1,000 treated;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

Table 50 Comparative effectiveness of behavioral interventions on severity of UI in adults

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Outcomes - Severity of Stress UI
Bo, 2000 ^720^ | PFMT with 8–12 maximum contractions in 3 series/day and 45 minutes/week group sessions | Untreated control group. Outcome: problems with interference with social life | 1/29 | 12/30 | 3.70 | 40.70 | 0.09 | 3 | 370
N = 59 | | | | | | | (0.01; 0.62) | (2; 6) | (154;402)A
100% female | | Outcome: problem with interference with physical activity | 13/29 | 24/30 | 43.50 | 79.30 | 0.56 | 3 | 358
6 month followup | | | | | | | (0.36; 0.87) | (2; 10) | (507; 102)A
Outcomes - Severity of Any UI
Lagro-Janssen, 1992 ^280^ | PFMT alone (stress) or BT (urge) or its combination (mixed) | Usual care | 4/54 | 23/56 | 7.41 | 41.07 | 0.18 | 3 | 337
N = 106 | | Outcome-severe UI | | | | | (0.07; 0.49) | (3; 5) | (211; 383)A
100% female
3 month followup
McFall, 2000 ^291^ | Community-based intervention: BT, managing the urge to urinate, and PFMT | Usual care. | 42/72 | 62/73 | 58.90 | 85.20 | 0.69 | 4 | 263
N = 145 | | Outcome: self-reported bothersomeness of UI | | | | | (0.55; 0.85) | (3; 8) | (124; 381)A
100% female | | Outcome: use absorbent pads for UI | 39/72 | 56/73 | 54.00 | 77.00 | 0.71 | 4 | 230
3 month followup | | | | | | | (0.55; 0.90) | (3; 14) | (74; 345)A
Fantl, 1991 ^281^ | BT (6 weekly visits) included patient education; voiding schedule and positive reinforcement | Usual care | 5/65 | 28/66 | 8.00 | 43.00 | 0.18 | 3 | 350
N = 131 | | Outcome: increase in episodes of UI | | | | | (0.07; 0.44) | (3; 4) | (241; 398)A
100% female
1.5 month followup
Chiarelli, 2002 ^246^ * | Training in PFMT and incorporated strategies to improve adherence | Usual postpartum care outcome: severe mixed UI | 37/370 | 59/350 | 10.10 | 16.80 | 0.59 | 15 | 67
N = 720 | | | | | | | (0.40; 0.87) | (10; 46) | (22; 100)A
100% female
3 month followup

* Sampling of continent adults at baseline;

Bold - significant differences in outcomes at 95% confidence level;

PFMT - pelvic floor muscle training, BFB - biofeedback; BT - bladder training;

A - number of avoided events per 1,000 treated;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

#### Level of evidence

The evidence from RCTs (level I) was analyzed to compare the effects of behavioral interventions on UI.

#### Summary

In conclusion, behavioral interventions resulted in improvement in UI across RCTs, but the estimation of the overall effect was difficult due to heterogeneity between studies. The long-term continence outcomes among subjects that experienced improvement while participating in RCTs are restricted to 1 year of followup. Several large well-designed RCTs reported a significant benefit of behavioral interventions on cure of incontinence with greater effects on stress UI in females and very limited evidence on urge incontinence and male incontinence. Weight reduction in combination with physical activity showed promising protection against incident UI. Preventive complex pelvic floor rehabilitation programs in specific populations, including males undergoing prostate surgery and pregnant women, demonstrated relative benefit on several measures of urinary continence. The effects on quality of life and objective instrumental outcomes are inconsistent and small. Active interventions provided better outcomes compared to usual care with no relative benefit compared to each other.

### Effects of Physiotherapeutic Interventions on UI in Community Dwelling Adults

Electrical or magnetic stimulation of pelvic floor muscles were examined in 17 RCTs ^293^ – ^295,^ ^297,^ ^298,^ ^300^ – ^302,^ ^512,^ ^735^ – ^742^ and one large prospective cohort study, ^304^ and neuromodulation of sacral nerve roots in nine RCTs ^296,^ ^303,^ ^305,^ ^306,^ ^743^ – ^747^ (Appendix Table F100). One RCT examined the effects of massage and stretching of perineum during the second stage of labor with a water soluble lubricant ^514^ and one study examined the effects of acupuncture to improve UI. ^748^ The majority of RCTs included less than 100 subjects; only three RCTs included more than 100 patients. ^302,^ ^736,^ ^746^

#### Patient outcomes

##### Continence in community dwelling females

Urinary continence after electrical stimulation in females was reported in five RCTs (Appendix Table F101) ^293^ – ^295,^ ^297,^ ^298^ and the effects of neuromodulation in one RCT. ^296^ The rates of cure from urge UI were more than 70 percent in one RCT after functional magnetic stimulation. ^298^ Electrical stimulation resulted in continence in about 20 percent of women. ^293,^ ^294^ The significant relative benefit of active magnetic to sham stimulation was shown in only one trial (RR 3.5, 95 percent CI 1.6; 7.8). ^298^ Other RCTs did not demonstrate significant relative benefit of cure compared to Kegel exercises, ^293^ biofeedback assisted training, ^297^ or placebo stimulation. ^295^ Magnetic stimulation of sacral roots did not provide better continence rates compared to sham neuromodulation. ^296^

In community dwelling adults, implantation of a multiprogrammable neurostimulator cured 47 percent of adults with urge UI ^305^ with significant relative benefit compared to standard medical therapy (RR 43.5, 95 percent CI 2.7; 695). ^305^ Sacral root neuromodulation resulted in urge continence more than nine times more often than conservative management with medications or pelvic floor muscle training (RR 9.9, 95 percent CI 1.4; 71.4). ^306^

Studies that examine the effects of electrical stimulation of pelvic floor failed to provide relative cure more often than control treatments. ^300,^ ^301^

##### Improvement in UI in community dwelling females

Several RCTs reported improvement in UI after stimulation in females; ^293^ – ^297,^ ^302,^ ^303,^ ^735,^ ^737,^ ^740,^ ^745^ with an improvement rate from 8 percent after percutaneous neuromodulation ^303^ to 85 percent after intravaginal stimulation ^737^ (Appendix Table F102). The improvement after magnetic stimulation varied from 23 percent in urge UI after electrical ^298^ to 74 percent in stress UI after neuromodulation therapy. ^296^ The greatest improvement in urge UI (85 percent) was observed after intravaginal electrical stimulation in women with predominantly urge UI. ^737^ The greatest improvement in stress UI (74 percent) was reported in women with mild stress incontinence after magnetic stimulation of sacral roots. ^296^ The rates of quantitative improvement were less than qualitative from 38 percent after neuromodulation ^303^ to 46 percent after electrical stimulation ^294^ in rates of negative pad test and only 15 percent in daily pad usage. ^303^ Transvaginal electric stimulation for 40 minutes/day was more effective than sham stimulation in women with either UI due to detrusor instability or stress UI, or both (mixed incontinence) (RR 2.1, 95 percent CI 1.1; 4.1). ^302^ However, the superiority of electrical stimulation compared to placebo treatment or regular care was not confirmed in other RCTs. ^294,^ ^737,^ ^740^

Magnetic neuromodulation of sacral roots compared to placebo improved UI twice as often in women with stress UI (RR 2.3, 95 percent CI 1.3; 4.0). ^296^ Magnetic stimulation of pelvic floor, in contrast, did not improve predominant urge UI. ^740^ However, abdominal pain related to urge UI was reported less often after magnetic stimulation compared to placebo (RR 8.1, 95 percent CI 1.1; 57.9). ^740^

Electrical stimulation was not more effective than Kegel exercises. ^293,^ ^735^ Home-managed electrical stimulation with vaginal/anal stimulators for at least 3 months reduced the frequency of urine loss in a large prospective cohort of Norwegian women (RR 0.7, 95 percent CI 0.7; 0.8). ^304^

Neuromodulation with surgical first stage lead placement compared to percutaneous needle electrode significantly improved refractory urge UI in women who failed medical, behavioral, and pelvic floor reeducation management. ^303^

##### UI in community dwelling females

Electrical ^302,^ ^739^ and magnetic ^740^ stimulation of pelvic floor and neuromodulation ^745^ did not reduce the prevalence of urge UI and detrusor over-activity compared to sham treatment (Appendix Table F103). Intravaginal electrical stimulation did not decrease the progression of mixed UI compared to Kegel exercises. ^735^ One prospective cohort study showed a significant reduction in frequency of urine loss and self perceived severity of UI. ^304^

One RCT of acupuncture in 85 women older than 18 years with symptoms of overactive bladder with urge UI did not significantly reduce self-reported severity of urge UI and did not improve the Urinary Distress Inventory scores or urodynamic outcomes compared to placebo acupuncture treatment designed to promote relaxation. ^748^ However, a small reduction in the number of total UI episodes (mean difference -0.6, 95 percent CI -1; -0.1) was detected compared to placebo treatment.

##### Continence in community dwelling adults

Electrical stimulation of pelvic floor ^301^ or neuromodulation ^305,^ ^306,^ ^744^ resulted in urinary continence in males and females in several RCTs (Appendix Table F104). The rates of continence varied from 8 percent after electrical ^300^ to 47 percent after neuromodulation. ^305^ The highest continence rate (>40 percent) was achieved with a sacral neurostimulator in patients with refractory urinary urge incontinence. ^305,^ ^306^ Electrical stimulation with intravaginal electrodes in women and anal in men resulted in continence in a small proportion of subjects with no relative benefit compared to sham treatment. ^300^ Larger cure rates were substantially higher after subcutaneous implantation of a multiprogrammable neurostimulator in the lower quadrant of the abdomen with the lead positioned to target sacral nerve compared to standard medical care (RR 43.5, 95 percent CI 2.7; 695.0). ^305^ Sacral root stimulation compared to prior conservative management, including medications and pelvic floor muscle training, cured urge UI (RR 9.9, 95 percent CI 1.4; 71.4). ^306^ Both trials showed a wide 95 percent CI because of zero ^305^ or only one case of improvement ^306^ after control interventions.

##### Improvement in UI in community dwelling adults

Stimulation improved UI with rates varying from 0.5 percent after electrical stimulation of pelvic floor ^512^ to 77 percent after neuromodulation of sacral nerve roots ^305^ (Appendix Table F105). Functional magnetic stimulation improved UI in 30 percent of 32 patients with UI due to detrusor overactivity. ^512^ The highest rate of improvement in urge UI (89.7 percent) was observed after combined therapy of Stoller afferent neuromodulation and 5mg of oral oxybutynin hydrochloride with no significant relative benefit compared to stimulation alone. ^744^ Implantation of a multiprogrammable sacral neurostimulator improved severe urge incontinence (RR 8.8, 95 percent CI 3.4; 22.8) and increased the proportion of patients who did not need to use absorbent pads (RR 23.0, 95 percent CI 3.2; 162.9) compared to standard care. ^305^ A significant reduction was also seen in daily urge incontinent episodes (>50 percent) (RR 6.6, 95 percent CI 1.6; 27.5). ^305^ Electrical stimulation did not show relative benefit compared to sham treatment in an underpowered RCT of 68 patients with UI due to detrusor overactivity. ^301^

#### Surrogate outcomes

##### Subjective measures of severity and quality of life of UI in community dwelling females

The effects of electrical stimulation on frequency and amount of urine loss were compared to sham treatment or behavioral interventions (Appendix Table F106). Only two RCTs reported significant relative differences in urinary leakage episodes after active compared to sham stimulation. Women with urodynamically proven stress incontinence reported a 12 percent reduction in incontinence episodes (mean difference -0.7, 95 percent CI -1.3; -0.1) and a 6 percent reduction in pad use compared to placebo treatment (mean difference -0.7, 95 percent CI -1.3; -0.1). ^294^ Women with stress, urge, or mixed UI experienced a 59 percent reduction in urinary leakage after transvaginal electrical stimulation with adjustable current intensity compared to inactive stimulation (mean difference -1.8, 95 percent CI -2.6; -0.9). ^742^

The impact on quality of life of UI was measured using the Urogenital Distress Inventory scores, the Incontinence Impact Questionnaire, and the Visual Analog Scale of UI. Only one RCT showed a significant improvement in quality of life from the complex pelvic floor rehabilitation program that included electrical stimulation of the pelvic floor muscle combined with an assisted pelvic floor muscle training program in premenopausal women with persistent postnatal stress UI. ^267^

##### Objective measures of severity of UI in community dwelling females

Severity of UI after electrical stimulation was estimated with the pad test and urodynamic cystometry (Appendix Table F107). Random changes or small improvements compared to control interventions were reported in the majority of the RCTs. The largest improvement was seen in pelvic floor muscle maximum strength (mean difference 0.9, 95 percent CI 0.3; 1.6, 194 percent compared to control) and changes from baseline in maximum rate of force development (mean difference 0.9, 95 percent CI 0.3; 1.6, 201 percent compared to control) after a complex pelvic floor rehabilitation program in women with persistent postnatal stress UI compared to relaxation massage for the back and extremities. ^267^

##### Subjective measure of severity of UI in community dwelling adults

The effects of electrical stimulation or neuromodulation on the frequency and amount of urine loss were compared to sham treatment or behavioral interventions (Appendix Table F108).

Sacral root neuromodulation with an implantable impulse generator reduced pad use for urge UI by 28 percent and leakage episodes of urge UI by 18 percent compared to the control group in patients with refractory urge incontinence. ^306^ The same effect was observed in another RCT after implantation of a multiprogrammable neurostimulator; severity rank of urge UI was decreased by 78 percent; pad use was decreased by 29 percent, and urge incontinence episodes by 14 percent compared to sham treatment. ^305^

##### Objective measure of severity of UI in community dwelling adults

The effects of electrical stimulation or neuromodulation on the frequency and amount of urine loss were reported compared to sham treatments or active controls (Appendix Table F109). ^300,^ ^301,^ ^746^ Functional magnetic stimulation compared to electrical stimulation did not show differences in urodynamic outcomes in patients with UI due to detrusor overactivity. ^512^

##### Events attributable to stimulation therapy

We estimated that functional magnetic stimulation would avoid 390 cases of urge UI per 1,000 treated women (Table 51). Transvaginal electric stimulation with individually adjusted intensity would result in improvement in UI in 180 women per 1,000 treated. ^302^ Home-managed electrical stimulation with vaginal/anal stimulators would avoid 50 cases of UI per 1,000 treated women (Table 52). ^304^

Table 51 Comparative effectiveness of electrical stimulation or neuromodulation on UI in adults

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Urge specific Continence
But, 2003 ^298^ | Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz | Placebo treatment with sham not active device. | 24/30 | 5/22 | 79.00 | 22.00 | 3.52 | 2 | 570
N = 52 | | Outcome: success of treatment | | | | | (1.60; 7.76) | (1; 8) | (131; 1,488)E
100% female | | Outcome: Cured from urge UI | 12/30 | 0/22 | 40.00 | 0 | 18.55 | 3 | 390 E
2 month followup | | | | | | | (1.16; 297.42)
Schmidt, 1999 ^305^ | Neuromodulation Therapy: Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place. | Standard medical therapy | 24/52 | 0/46 | 47.00 | 0 | 43.45 | 2 | 460E
N = 98 | | Outcome: cured from urge UI | | | | | (2.72; 695.03)
81% female
5 month followup
Weil, 2000 ^306^ | Neuromodulation Therapy: Sacral root neuromodulation with an implantable impulse generator | Prior conservative management: medications or PFMT | 9/21 | 1/23 | 42.86 | 4.35 | 9.86 | 3 | 385
N = 44 | | Outcome: cured from urge UI | | | | | (1.36; 71.36) | (0; 64) | (16; 3,059)E
91% female
36 month followup
Improvement in Stress UI
Fujishiro, 2000 ^296^ | Neuromodulation Therapy: Magnetic stimulation of sacral roots with 15Hz frequency, 50% intensity output for 5 seconds per minute for 30 minutes | Sham stimulation with inactive device | 23/31 | 10/31 | 74.00 | 32.00 | 2.30 | 2 | 420
N = 62 | | Outcome: improved stress UI | | | | | (1.33; 3.99) | (1; 10) | (57;104)E
100% female
1 week followup
Improvement in UI
Brubaker, 1997 ^302^ | Transvaginal electric stimulation for 20 minutes 2 times/day using frequency of 20Hz, a 2-second - 4-second work-rest cycle with a range of stimulation intensities, from 0 to 100mA | Sham inactive device | 21/61 | 10/60 | 35.00 | 17.00 | 2.14 | 6 | 180
N = 148 | | Outcome: improved UI | | | | | (1.10; 4.14) | (2; 59) | (17; 535)E
100% female
2 month followup
Borawski, 2007 ^303^ | Neuromodulation Therapy: Electrical stimulation with percutaneous needle electrode (22-G spinal needle) placement | Electrical stimulation with surgical first stage lead placement: >50% improvement in 24 hour pad weight | 4/13 | 13/17 | 30.77 | 76.47 | 0.40 | 2 | 457
N = 30 | | | | | | | (0.17; 0.95) | (2; 25) | (40; 634)A
100% female | | >50% Improvement in 24 hour pad usage | 2/13 | 11/17 | 15.38 | 64.71 | 0.24 | 2 | 493
2 week followup | | | | | | | (0.06; 0.89) | (2; 14) | (70; 606)A
| | >50% Improvement in daily incontinence episodes | 1/13 | 14/17 | 7.69 | 82.35 | 0.09 | 1 | 747
| | | | | | | (0.01; 0.62) | (1; 3) | (311; 812)A
Improvement in Urge UI
But, 2003 ^298^ | Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz | Placebo treatment with sham not active device. | 11/30 | 1/22 | 36.70 | 5.00 | 8.07 | 3 | 317
N = 52 | | Outcome- Less abdominal pain related to urge UI | | | | | (1.12; 57.95) | (0; 163) | (6; 2,847)E
100% female
2 month followup
Schmidt, 1999 ^305^ | Neuromodulation Therapy: Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place | Standard medical therapy. | 40/52 | 4/46 | 77.00 | 8.00 | 8.85 | 1 | 690
N = 98 | | Improvement in severity: heavy urge incontinence at baseline and none at 5 months | | | | | (3.43; 22.83) | (1; 5) | (194; 1,747)E
81% female | | Significant reduction in daily urge UI episodes (>50%) | 15/52 | 2/46 | 29.00 | 5.00 | 6.63 | 4 | 240
5 month followup | | | | | | | (1.60; 27.48) | (1; 33) | (30; 1,324)E
| | No need of absorbent pads or diapers for urge UI | 26/52 | 1/46 | 50.00 | 2.00 | 23.00 | 2 | 480
| | | | | | | (3.25; 162.88) | (0; 22) | (45; 3,238)E

Bold - significant differences in outcomes at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

A - number of avoided and E - number of excessive events per 1,000 treated.

Table 52 Comparative effectiveness of electrical stimulation on any UI in adults

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Analyzed | Number of Cases After Control Treatment/ Number Analyzed | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Outcome - UI
Spruijt, 2003 ^735^ | Intravaginal electrical stimulation of the pelvic floor using stimulator generated biphasic current pulses with a duration of 1ms and a frequency of 50Hz (stress) or 20Hz (urge) | Kegel PFMT with verbal instructions on how to exercise at home | 6/25 | 7/12 | 25.00 | 54.50 | 0.41 | 3 | 295
N = 51 | | | | | | | (0.18; 0.96) | (2; 44) | (23; 449)A
100% female
2 month followup
Progression of UI
Indrekvam, 2001 | Home-managed electrical stimulation with vaginal/anal stimulators (20–50Hz) | Baseline data. | 331/3008 | 451/3008 | 11.00 | 15.00 | 0.73 | 25 | 40
N = 3,008 | | Outcome: substantial amounts of usual leakage | | | | | (0.64; 0.84) | (19; 41) | (24; 54)A
100% female | | Pad use >5 during 24 hours | 391 | 632 | 13.00 | 21.00 | 0.62 | 13 | 80
3 month followup | | | | | | | (0.55; 0.69) | (11; 16) | (64; 94)A

Bold - significant differences in outcomes at 95% confidence level;

PFMT - pelvic floor muscle training;

A - number of avoided events per 1,000 treated

Sacral nerve stimulation would avoid 385 ^306^ to 460 ^305^ cases of urge UI per 1,000 treated adults. Electrical stimulation with surgical first stage lead placement would improve UI in more than 400 women per 1,000 treated compared to placebo. ^303^

#### Summary

In conclusion, evidence from several small RCTs (<100 subjects), three large RCTs, and one prospective cohort suggested that electrical and magnetic stimulation of pelvic floor and sacral nerve roots neuromodulation can improve predominantly urge UI in adults but the curative effects are not consistent.

### Effects of Medical Devices on UI in Community Dwelling Females

Eight RCTs examined different devices to treat UI in females, including Hodge pessary, ^311^ disposable intravaginal devices, ^312,^ ^313^ urethral plug, ^314^ and vaginal cones ^299,^ ^315,^ ^316^ (Appendix Table F110).

#### Patient outcomes

##### Continence and improvement of UI in community dwelling females

A new blocking leakage urethral sterile device with disposable applicator resulted in the highest continence rate (67 percent) in women with mixed or stress UI with no relative benefit compared to a sterile balloon device (Appendix Table F111). ^313^ Continence during physical activity was achieved in 36 percent of exercisers ages 33–73 with stress UI after using a Hodge pessary but there was no relative benefit compared to a super tampon. ^311^ A Conveen continence disposable intravaginal device cured stress UI in 36 percent compared to 48 percent with a Contrelle continence tampon with no statistically significant difference between treatments.

The use of vaginal cones of 20, 40, and 70g for 20 minutes/day resulted in nonsignificant improvement in subjective and objective cure in women with clinically and urodynamically proven stress UI. ^299^ Use of vaginal cones showed no improvement in UI compared to pelvic floor muscle training and functional electrical stimulation biofeedback. ^315^

##### Severity of UI and quality of life with UI in community dwelling females

A continence disposable intravaginal device and tampon reduced urine loss during the 24-hour pad weight test compared to no treatment. ^312^

Vaginal cones did not improve the results of the stress pad test and the 24-hour pad weight test compared to no treatment but improved the leakage index. ^299^ Vaginal cones were not more effective in reducing self-reported severity of UI than biofeedback assisted pelvic floor muscle training ^315^ or regular care ^299^ (Appendix Table F112). The effects of vaginal cones on restricting exercise and avoiding places due to incontinence were less than those of biofeedback-assisted pelvic floor muscle training. ^315^

##### UI in community dwelling males

Two RCTs examined medical devices on UI in males (Appendix Table F113). ^317,^ ^318^ One small RCT did not show a relative benefit of a UroLume sphincteric stent inserted cystoscopically to conventional external sphincterotomy in 57 men with spinal cord injury and electromyographic and manometric evidence of external detrusor-sphincter dyssynergia (Appendix Table F114). ^317^ A second small crossover RCT compared penile compression devices in men 6 months after radical prostatectomy ^318^ and did not show differences in resistance index and urine loss during the 4-hour pad test compared to no device (Appendix Table F115).

In conclusion, limited evidence suggests that medical devices result in modest improvement in UI in women with a tendency to provide relative benefit compared to no treatments but not to other interventions.

### Effects of Bulking Agents on UI in Community Dwelling Females

The effects of different bulking agents on female UI were examined in two RCTs with more than 100 females ^307,^ ^749^ and three smaller RCTs ^309,^ ^310,^ ^750^ with 6–24 months of followup (Appendix Table F116).

#### Outcomes

##### Continence

Curative effects at 12 months of followup were shown after intraurethral collagen injection in women with stress UI (51.5 percent were dry during 24-hour pad test) (Appendix Table F117). ^307^ Transurethral porcine dermal implant injection resulted in negative pad test (cure) in 60 percent of women with urodynamically proven stress UI at 6 months of followup. ^309^ Peri-urethral injections of autologous fat from the anterior abdominal wall or buttock with up to three injections depending on individual response cured or improved UI at 24 months of followup in 17 percent of women with stress UI. ^750^ Transurethral injection of the bulking agent, dextran copolymer, resulted in objective cure at 12 months of followup in 15 percent of women with stress or mixed incontinence with minor and controlled urge component, who failed prior conservative treatments. ^310^

##### Improvement in UI

Four RCTs reported improvement in UI after bulking agents. The highest rates of improvement (60 percent of women had an improved pad test) were reported after periurethral porcine dermal implant injection. ^309^ The same treatment improved the UI scores in 50 percent of women and the results of the Kings College Hospital Quality of Health Questionnaire in 56 percent. ^309^ Injection of the bulking agent Durasphere improved UI in 43 percent of women with refractory stress UI due to intrinsic sphincter deficiency. ^749^

##### UI

The risk of complete urinary retention was lower after intraurethral collagen submucosal injection compared to surgical procedures, including needle bladder neck suspensions, Burch colposuspensions, and intravaginal slings (RR 0.1, 95 percent CI 0.0; 0.9). However, no RCTs showed a significant relative benefit of bulking agents compared to placebo ^750^ or other treatments. ^307,^ ^309,^ ^310,^ ^749^ The incidence of urgency was higher after the synthetic bulking agent compared to bovine collagen (RR 2.1, 95 percent CI 1.3; 3.3). ^749^ Bulking agents did not result in consistent improvement in urodynamic outcomes, pad weight test results, or quality of life measures (Appendix Table F118). We estimated that 119 patients would avoid complete urinary retention after collagen injection compared to surgical interventions (Table 53). In conclusion, no evidence suggests that bulking agents improve efficacy compared to placebo or effectiveness compared to other treatments in females.

Table 53 Comparative effectiveness of bulking agents on UI in females

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 treated
Sample | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Outcome - Urgency
Lightner 2001 ^749^ | Injection of bulking agent 1.0ml durasphere maximum 5 times with a minimum 7 day interval | Injection of bulking agent bovine collagen maximum 5 times with a minimum 7 day interval | 43/176 | 22/188 | 24.70 | 11.90 | 2.09 | 8 | 128
N = 355 | | | | | | | (1.30; 3.34) | (4; 28) | (36; 279)E
100% female
12 month followup
Outcome - Complete Retention
Corcos, 2005 ^307^ | Intraurethral collagen sub mucosal injection | Surgery (needle bladder neck suspensions, Burch, and slings) | 1/66 | 9/67 | 1.52 | 13.43 | 0.11 | 8 | 119
N = 133 | | | | | | | (0.01; 0.87) | (8; 55) | (18; 132)A
100% female
12 month followup

Bold - significant differences in outcomes at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

Transurethral radiofrequency energy collagen micro-remodeling was examined in one RCT of 110 women with stress UI and showed no significant improvement in a quality of life questionnaire in women with stress UI and bladder outlet hypermobility compared to placebo injections. ^751^

### Clinical Effects of Obstetric Interventions on UI

#### Patient outcome - UI

The effects of different obstetric strategies to reduce the risk of UI were examined in seven large RCTs ^386^ – ^389,^ ^391,^ ^752,^ ^753^ and one smaller RCT ^382^ with justified sample size that evaluated surgical techniques for the primary repair of obstetric anal sphincter lacerations on UI (Appendix Table F119). Planned Cesarean delivery compared to vaginal birth reduced the risk of stress UI by 40 percent (RR 0.6, 95 percent CI 0.4; 0.9) at 3 months but not 2 years postpartum (Appendix Table F120). ^389^ Caesarean section was more protective against UI compared to vaginal delivery 3 months postpartum in the large RCT with no intention to treat and a 4.3 percent rate of cross treatments decided by the attending physician. ^752^ Caesarean section reduced the risk of any UI by 70 percent (RR 0.3, 95 percent CI 0.1; 0.7) in primiparous women and in the subgroup of primiparous women with a history of UI (RR 0.3, 95 percent CI 0.1; 0.9). ^752^ The risk of stress UI was reduced by 70 percent in primiparous women (RR 0.3, 95 percent CI 0.2; 0.5), with the same reduction in females with and without previous UI. The protective effect was not seen in multiparous women.

Restrictive vs. liberal policies for episiotomy ^386,^ ^753^ did not reduce the risk of UI 1.5–3 years postpartum. Mediolateral episiotomy compared to no episiotomy ^387^ did not decrease the risk of stress or urge UI 3 months after delivery. The same proportion of women requiring assisted vaginal delivery reported stress and urge UI after delivery with vacuum extractor or forceps delivery 5 years postpartum. ^391^ End-to-end repair compared to overlapping technique did not result in a lower risk of UI in 51 women with complete third or fourth degree anal sphincter laceration who underwent primary repair at the time of vaginal delivery. ^382^ Episiotomy did not affect urodynamic outcomes (Appendix Table F121). ^386,^ ^387^

### Effects of Hysterectomy on UI

#### Patient outcome - UI

Three powered RCTs ^320,^ ^754,^ ^755^ and two smaller RCTs with no justification for sample size ^319,^ ^756^ examined the effects of hysterectomy on the incidence and progression of UI (Appendix Table F122). Total abdominal hysterectomy was compared to subtotal supracervical hysterectomy in women with benign diseases of the uterus (Appendix Table 123). No differences in total, urge, or stress UI were detected between the two treatments. Intrafascial total abdominal hysterectomy significantly reduced the risk of urge UI compared to the extrafascial approach. ^319^

#### Surrogate outcome - Objective measures of severity of UI

Two RCTs evaluated urodynamic outcomes and self-reported severity of UI and did not show differences between subtotal and total hysterectomy (Appendix Table F124). ^754,^ ^756^

### Effects of Vaginal Tapes and Sling Procedures on UI

The effects of vaginal tapes and sling procedures to reduce the progression of UI in women with predominantly stress UI were examined in 25 RCTs (Appendix Table F125). ^325,^ ^327,^ ^331,^ ^338,^ ^749,^ ^757,^ ^758^ ^323^ , ^324,^ ^326,^ ^329,^ ^332^ – ^337,^ ^339^ – ^342,^ ^485,^ ^488,^ ^491,^ ^759,^ ^760^

#### Patient outcomes

##### Continence (curative effects)

The majority of the RCTs (20/25) reported continence after vaginal tapes and sling procedures (Appendix Table F126). ^323^ – ^342^ The sample size included more than 100 women in nine RCTs. ^325^ – ^327,^ ^331,^ ^332,^ ^334,^ ^340,^ ^341^ The rate of continence was above 75 percent in the majority of RCTs; only two RCTs reported cure rates <75 percent, ^334,^ ^337^ All RCTs compared the effectiveness of vaginal tapes and sling procedures to active controls; no efficacy trials were identified. Cure rates were comparable after all tested procedures with no significant relative benefits. Only two RCTs reported significant relative increase in objective cure. ^330,^ ^331^ Tension-free vaginal tape procedures increased the rate of negative postoperative cough provocation tests by 60 percent compared to plication of the endopelvic fascia (RR 1.6, 95 percent CI 1.1; 1.4) in a small trial that examined women with severe genital prolapse treated with vaginal hysterectomy, culdoplasty, and cystocele repair for pelvic floor defects. ^330^ Tension-free vaginal tape under local anesthesia with polypropylene mesh tape placed under the midurethra resulted in a negative stress test 50 percent more often than laparoscopic mesh colposuspension under general anesthesia (RR 1.5, 95 percent CI 1.1; 2.4). ^331^

##### Improvement of UI in females

The majority of RCTs reported improvement in UI after vaginal tape and sling procedures (Appendix Table F127). ^323,^ ^325^ – ^327,^ ^329,^ ^332,^ ^334,^ ^336,^ ^339,^ ^342,^ ^485,^ ^760^ The rates of improvement differed from 2.2 percent after transobturator suburethral sling procedure ^339^ to 100 percent after transvaginal antimicrobial mesh synthetic mesh, ^323^ depending on definitions of improvement. The rates were higher for stress UI after transvaginal antimicrobial synthetic mesh, ^323^ vesicourethral suspension by allogenic sling, ^485^ and suprapubic arc sling. ^760^ The rates were lower (19.4 percent) after the same procedure on quantitative improvement in stress UI defined as a decrease of >50 percent in urine loss. ^336^ The largest rate of improvement in urge UI (71.1 percent) was reported after intra-vaginal sling procedures. ^760^ A significant relative benefit was shown in one RCT that compared suburethral slingplasty with the suprapubic arc to intravaginal sling in 195 patients with urodynamic UI refractory to conservative management. Improvement in urge UI occurred 2.7 times more often after suprapubic arc compared to intravaginal sling (RR 2.7, 95 percent CI 1.3; 5.5). ^334^

##### UI in females

The effects of vaginal tape and sling procedures were evaluated on self-reported incontinence and quality of life and objective measures of severity of UI including the pad weight test (Appendix Table F128). Few trials reported significant reduction in the progression of stress UI. Persistent subjective symptoms of stress UI were reported less often after tension-free vaginal tape than suprapubic urethral support sling in one trial (RR 0.5, 95 percent CI 0.3; 0.9). ^341^ Tension-free vaginal tape reduced stress UI by 90 percent compared to plication of the endopelvic fascia in one trial (RR 0.1, 95 percent CI 0; 0.8. ^330^ Women after tension-free vaginal tape reported subjective treatment failure less often (RR 0.6, 95 percent CI 0.3; 0.9) compared to suprapubic urethral support sling in one trial. ^341^

#### Surrogate outcomes

##### Subjective measure of severity of UI

RCTs compared self-reported frequency and severity of UI and quality of life of UI after tape and sling procedures compared to other active treatments (Appendix Table F129). Inconsistent progression in UI was reported in one RCT after tension-free vaginal tape under local anesthesia compared to laparoscopic mesh colposuspension under general anesthesia (mean difference in UI Severity Score 1.6, 95 percent CI 0.27; 2.94, mean difference in Visual Analog Scale of UI 1.3, 95 percent CI 0.7; 2.1). ^331^ One RCT reported improvement in global discomfort related to UI after suburethral sling procedure with retropubic routes compared to transobturator routes (mean difference 0.5, 95 percent CI 0.1; 0.9). ^342^

##### Objective measure of severity of UI

Inconsistencies in direction and effect size in urodynamic cystometry after tested treatments were found in the majority of RCTs (Appendix Table F130).

### Effects of Surgical Interventions on UI in Community Dwelling Women (Appendix Table F131)

Six RCTs examined the effects of surgical treatments of prolapse to prevent UI. ^322,^ ^330,^ ^486,^ ^487,^ ^761,^ ^762^ One well designed RCT tested the effects of preoperative physiotherapy on UI. ^763^ The majority of RCTs included women with stress UI and compared different surgical techniques to treat UI. ^321,^ ^343^ – ^350,^ ^353^ – ^362,^ ^764^ – ^778^

#### Patient outcomes

##### Continence

Forty RCTs reported continence rates after different surgical procedures (Table 54). ^319,^ ^345^ – ^351,^ ^353,^ ^355^ – ^362,^ ^486,^ ^487,^ ^764,^ ^767^ – ^770,^ ^772^ – ^774,^ ^777,^ ^778^ ^321,^ ^343,^ ^344,^ ^491,^ ^757,^ ^766,^ ^771,^ ^775,^ ^776^ The definitions varied from subjective cure with no symptoms or complaints, and need for pad use to objective cure during urodynamic evaluation and stress test. The continence rates demonstrated a substantial variability after the same procedures from 3.1 percent ^770^ to 85.1 percent ^346^ after laparoscopic colposuspension and from 8.7 percent ^777^ to 93.3 percent ^490^ after laparoscopic Burch procedures. Burch retropubic urethropexy resulted in continence in more than 90 percent of women and provided the largest relative benefit compared to modified anterior colporrhaphy (RR 5.1, 95 percent CI 1.8; 14.1) ^353^ and anterior colporrhaphy with Kelly plication (RR 1.4, 95 percent CI 1.1; 1.8). ^345^ The relative benefit of continence after Burch urethropexy was larger in another RCT that examined the same procedures (RR 2.3, 95 percent CI 1.3; 3.8). ^774^ Burch colposuspension with abdominal hysterectomy compared to anterior colporrhaphy with vaginal hysterectomy resulted in higher continence rates (RR 1.6, 95 percent CI 1.1; 2.3) in women undergoing surgery for primary stress incontinence and a concurrent grade 2 or 3 cystocele. ^362^ The relative benefit of the same procedure differed depending on the definition of cure. For example, the same trial that showed a 60 percent relative benefit for urinary continence with the Burch procedure compared to anterior colporrhaphy reported a 300 percent relative benefit on cure defined as a negative cotton swab test (RR 3.2, 95 percent CI 1.6; 6.4). ^362^ The largest relative benefit of Burch retropubic suspension or pubovaginal sling was shown when compared with Oxybutynin 5mg three times/day (RR 41.3, 95percent CI 2.6; 645). ^769^

Table 54 Effects of surgical interventions on urinary continence in females (secondary prevention) (sorted by rate of urinary continence after active treatment, from highest to lowest)

Author | Active | Control | Definition of Continence | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Colombo, 1996 ^348^ | Burch colposuspension with placement of two couples of permanent polybutylate-coated polyester sutures | Abdominal paravaginal defect repair with 5–7 pairs of permanent braided silicone-coated polyester suture. | Cure as no incontinence episodes and no urine loss at stress test | 18/18 | 13/18 | 100.0 | 72.2 | 1.4
N = 36 | | | | | | | | (1.0; 1.8)
6 month followup
Laurikainen, 2007 ^491^ | Retropubic tension-free vaginal polypropylene tape procedure by Ulmsten | Transobturator tension-free vaginal polypropylene tape procedure by de Leval | Objective cure as negative stress test | 134/136 | 125/132 | 98.5 | 94.7 | 1.0
N = 273 | | | | | | | | (1.0; 1.1)
2 month followup
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Subjective cure as no self-reported urinary incontinence | 18/19 | 3/16 | 94.7 | 18.8 | 5.1 | 1 | 760
N = 35 | | | | | | | | (1.8; 14.1) | (0; 7) | (152; 2,454)E
12 month followup
Sand, 2000 ^358^ | Burch procedures with four 2-0 polytetrafluoroethylene sutures and tension placed on the periurethral sutures (modified Tanagho method) | Suburethral sling with continuous polytetraflouroethylene strip from rectus fascia into retropubic space and beneath urethra at urethrovesical junction level | Subjective cure | 18/19 | 17/17 | 94.7 | 100.0 | 1.0 | .
N = 36 | | | | | | | | (0.8; 1.1)
3 month followup
Zullo, 2001 ^361^ | Transperitoneal laparoscopic Burch procedure using nonabsorbable sutures | Transperitoneal laparoscopic Burch procedure using Prolene mesh fixed with tacks or staples | Subjective cure (visual analog scale) | 28/30 | 26/30 | 93.3 | 86.7 | 1.1
N = 60 | | | | | | | | (0.9; 1.3)
12 month followup
Schraffordt Koops, 2006 ^757^ | Previous surgery for prolapse/ incontinence +TVT performed with Ulmsten's method | No prior surgery + TVT performed with Ulmsten's method. | Cured - no leakage during physical activity, coughing or sneezing | 122/131 | 628/378 | 92.9 | 92.6 | 1.0
N = 809 | | | | | | | | (1.0; 1.1)
2–36 month followup
Gilja 1998, ^351^ | Burch retropubic urethropexy | Modified bladder neck suspension by Raz | Subjective cure from stress urinary incontinence as no leakage episodes and symptoms. | 52/56 | 39/46 | 92.9 | 84.8 | 1.1
N = 204 | | | | | | | | (0.9; 1.3)
36 month followup
Colombo, 1994 ^347^ | Burch colposuspension | Modified Marshall-Marchetti-Krantz urethropexy | Subjective cure as no incontinence symptoms | 37/40 | 34/40 | 92.5 | 85.0 | 1.1
N = 80 | | | | | | | | (0.9; 1.3)
24–84 month followup
Bergman, 1989 ^345^ | Burch urethropexy | Modified Pereyra needle urethropexy | Objective cure as no urine loss on cough profile during urodynamic evaluation at maximum cystometric capacity | 35/38 | 24/35 | 91.0 | 72.0 | 1.3 | 5 | 190
N = 127 | | | | | | | | (1.0; 1.7) | (2; 46) | (22; 470)E
12 month followup | Burch urethropexy | Anterior colporrhaphy with Kelly plication | Objective cure as no urine loss on cough profile during urodynamic evaluation at maximum cystometric capacity | 35/38 | 23/35 | 91.0 | 65.0 | 1.4 | 4 | 260
| | | | | | | | (1.1; 1.8) | (2; 18) | (55; 528)E
Gilja, 1998 ^351^ | Transvaginal Burch procedure | Modified bladder neck suspension by Raz | Subjective cure from stress urinary incontinence as no leakage episodes and symptoms | 40/44 | 39/46 | 90.9 | 84.8 | 1.1
N = 204 | | | | | | | | (0.9; 1.3)
36 month followup
Schraffordt Koops, 2006 ^757^ | Previous surgery for prolapse/ incontinence +TVT performed with Ulmsten's method | No prior surgery + TVT performed with Ulmsten's method | Cured. As no leakage during physical activity, coughing or sneezing | 119/131 | 636/378 | 90.5 | 93.8 | 1.0
N = 809 | | | | | | | | (0.9; 1.0)
2–36 month followup
Zullo, 2001 ^361^ | Transperitoneal laparoscopic Burch procedure using nonabsorbable sutures | Transperitoneal laparoscopic Burch procedure using Prolene mesh fixed with tacks or staples | Objective cure no urine loss during cough and Valsalva maneuver in standing position with bladder filled to maximal cystometric capacity | 27/30 | 23/30 | 90.0 | 76.7 | 1.2
N = 60 | | | | | | | | (0.9; 1.5)
12 month followup
Sand, 2000 ^358^ | Burch procedures with four 2-0 polytetrafluoroethylene sutures and tension placed on the periurethral sutures (modified Tanagho method) | Suburethral sling with continuous polytetraflouroethylene strip from rectus fascia into Retropubic space and beneath urethra at urethrovesical junction level | Objective cure | 17/19 | 17/17 | 89.5 | 100.0 | 0.9
N = 36 | | | | | | | | (0.7; 1.1)
3 month followup
Gilja, 1998 ^351^ | Burch retropubic urethropexy | Modified bladder neck suspension by Raz | Objective cure as no urine loss in urodynamic exam | 50/56 | 37/46 | 89.3 | 80.4 | 1.1
N = 204 | | | | | | | | (0.9; 1.3)
36 month followup
Bai, 2005 ^344^ | Burch colposuspension | Pubovaginal sling using autologous rectus muscle fascia | Cure from stress urinary incontinence | 29/33 | 26/28 | 87.9 | 92.9 | 0.9
N = 92 | | | | | | | | (0.8; 1.1)
12 month followup | | Tension-free vaginal tape | Cure from stress urinary incontinence | 29/33 | 27/31 | 87.9 | 87.1 | 1.0
| | | | | | | | (0.8; 1.2)
Gilja, 1998 ^351^ | Transvaginal Burch procedure | Modified bladder neck suspension by Raz | Objective cure as no urine loss in urodynamic exam | 38/44 | 37/46 | 86.4 | 80.4 | 1.1
N = 204 | | | | | | | | (0.9; 1.3)
36 month followup
Liapis, 2002 ^355^ | Burch colposuspension | Tension-free vaginal tape procedure | Objective cure as pad weight difference <1g | 30/35 | 30/36 | 86.0 | 84.0 | 1.0
N = 71 | | | | | | | | (0.8; 1.3)
24 month followup
Fatthy, 2001 ^350^ | Laparoscopic Burch colposuspension | Open Burch colposuspension | Cure from stress urinary incontinence (no symptoms, negative stress test and urodynamic continence) | 29/34 | 34/40 | 85.3 | 85.0 | 1.0
N = 74 | | | | | | | | (0.8; 1.2)
18 month followup
Cheon, 2003 ^346^ | Laparoscopic colposuspension | Burch open colposuspension | Objective cure as dry during severe cough on urodynamic testing | 40/47 | 37/43 | 85.1 | 86.0 | 1.0
N = 90 | | | | | | | | (0.8; 1.2)
12 month followup
Culligan, 2003 ^349^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension | Objective cure: negative stress test and negative pad-weight test | 16/19 | 17/17 | 84.6 | 100.0 | 0.8
N = 36 | | | | | | | | (0.7; 1.1)
72.6 month followup
Persson, 2002 ^770^ | Laparoscopic colposuspension | Tension-free vaginal tape by Ulmsten | Objective cure: Cured | 27/32 | 33/38 | 84.4 | 86.8 | 1.0
N = 79 | | | | | | | | (0.8; 1.2)
12 month followup
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Objective cure: negative cough and Valsalva test in the supine and standing positions, with the bladder filled to maximal cystometric capacity | 16/19 | 5/16 | 84.2 | 31.3 | 2.7 | 2 | 530
N = 35 | | | | | | | | (1.3; 5.7) | (1; 12) | (84; 1,475)E
12 month followup
Ustun, 2003 ^360^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Cure as no pad use and no urinary leakage in urodynamic exam | 19/23 | 19/23 | 82.6 | 82.6 | 1.0
N = 46 | | | | | | | | (0.8; 1.3)
18 month followup
Fatthy, 2001 ^350^ | Laparoscopic Burch colposuspension | Open Burch colposuspension | Negative stress test | 28/34 | 31/40 | 82.4 | 77.5 | 1.1
N = 74 | | | | | | | | (0.8; 1.3)
18 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | Subjective cure as no incontinence episodes | 30/37 | 17/34 | 81.1 | 50.0 | 1.6 | 3 (1; 17) | 311
N = 71 | | | | | | | | (1.1; 2.3) | | (60; 674)E
12 month followup
Su, 1997 ^359^ | Laparoscopic colposuspension | Open Burch colposuspension | Objective cure as no leakage during urodynamic exam | 37/46 | 44/46 | 80.4 | 95.6 | 0.8
N = 92 | | | | | | | | (0.7; 1.0)
12 month followup
Osman, 2003 ^769^ | Burch retropubic suspension or pubovaginal sling | Oxybutynin hydrochloride 5mg 3 times/day | Complete urinary continence | 40/50 | 0/25 | 80.0 | 0.0 | 41.3 | 1 | 800E
N = 75 | | | | | | | | (2.6; 645.0)
6 month followup
Quadri, 1999 ^357^ | Burch colposuspension | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | Objective cure | 12/15 | 15/15 | 80.0 | 100.0 | 0.8
N = 30 | | | | | | | | (0.6; 1.1)
12 month followup
Colombo, 1994 ^347^ | Burch colposuspension | Modified Marshall-Marchetti-Krantz urethropexy | Objective cure as no urine loss at stress test | 32/40 | 26/40 | 80.0 | 65.0 | 1.2
N = 80 | | | | | | | | (0.9; 1.6)
24–84 month followup
Lalos, 1993 ^354^ | Retropubic urethrocystopexy | Pubococcygeal repair | Subjective cure as self-reported urinary continence | 17/22 | 11/14 | 77.3 | 78.6 | 1.0
N = 36 | | | | | | | | (0.7; 1.4)
12 month followup
Ankarda, 2005 ^775^ | Open Burch colposuspension using sutures | Laparoscopic colposuspension using mesh and staples | Subjectively dry | 58/79 | 45/53 | 73.4 | 84.9 | 0.9
N = 211 | | | | | | | | (0.7; 1.0)
12 month followup
Berglund, 1996 ^768^ | Retropubic urethrocystopexy | Pubococcygeal repair | Subjective cure as self-reported urinary continence | 22/30 | 12/15 | 73.3 | 80.0 | 0.9
N = 45 | | | | | | | | (0.7; 1.3)
12 month followup
El-Barky, 2005 ^766^ | Burch colposuspension | Tension-free vaginal tape procedure | Cured from urinary stress incontinence | 18/25 | 18/25 | 72.0 | 72.0 | 1.0
N = 50 | | | | | | | | (0.7; 1.4)
6 month followup
Bergman, 1995 ^774^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | Objective cure as no urine loss on cough profile during urodynamic evaluation at maximum cystometric capacity | 27/38 | 11/35 | 71.1 | 31.4 | 2.3 | 3 (1; 10) | 396
N = 127 | | | | | | | | (1.3; 3.8) | | (104; 893)E
60 month followup | | Modified Pereyra needle urethropexy | | 27/38 | 13/35 | 71.1 | 37.1 | 1.9 | 3 | 339
| | | | | | | | (1.2; 3.1) | (1; 14) | (70; 773)E
Ankardal, 2004 ^776^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | Subjectively dry | 85/120 | 64/120 | 70.8 | 53.3 | 1.3 | 6 | 175
N = 240 | | | | | | | | (1.1; 1.6) | (3; 22) | (45; 334)E
12 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | Objective cure as negative stress test result | 26/37 | 14/34 | 70.3 | 41.2 | 1.7 | 3 | 291
N = 71 | | | | | | | | (1.1; 2.7) | (1; 29) | (35; 694)E
12 month followup
Demirci, 2001 ^764^ | Burch colposuspension (Tanagho), 9 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy. | McGuire's free-rectus fascial sling from inferior leaf of rectus fascia; 8 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy | Urinary continence (dry) | 16/23 | 15/23 | 69.6 | 65.2 | 1.1
N = 46 | | | | | | | | (0.7; 1.6)
12–13 month followup
Berglund, 1996 ^768^ | Retropubic urethrocystopexy | Pubococcygeal repair | Objective cure as negative pad test | 20/30 | 7/15 | 66.7 | 46.7 | 1.4
N = 45 | | | | | | | | (0.8; 2.6)
12 month followup
Quadri, 1999 ^357^ | Burch colposuspension | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | Subjective cure | 10/15 | 15/15 | 66.7 | 100.0 | 0.7 | 3 | 333
N = 30 | | | | | | | | (0.5; 1.0) | (2; 42) | (24; 530)A
12 month followup
Kitchener, 2006 ^771^ | Laparoscopic colposuspension | Open abdominal retropubic colposuspension | Objective cure (<1g pad test) | 98/147 | 82/144 | 66.7 | 56.9 | 1.2
N = 291 | | | | | | | | (1.0; 1.4)
24 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | Negative cotton swab test | 24/37 | 7/34 | 64.9 | 20.6 | 3.2 | 2 | 443
N = 71 | | | | | | | | (1.6; 6.4) | (1; 9) | (116; 1,102)E
12 month followup
Persson, 2000 ^356^ | Laparoscopic Burch colposuspension using one double-bite of polytetrafluoro-ethylene sutures | Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoroethylene sutures | Subjective cure | 50/78 | 72/83 | 64.1 | 86.7 | 0.7 | 4 | 226
N = 161 | | | | | | | | (0.6; 0.9) | (3; 10) | (95; 335)A
12 month followup
Wang, 2003 ^767^ | Modified Burch colposuspension | Tension-free vaginal taping | Objective cure as pad weight<2g and negative stress urodynamic test | 31/49 | 40/49 | 63.3 | 81.6 | 0.8
N = 98 | | | | | | | | (0.6; 1.0)
12 month followup
Colombo, 1997 ^486^ | Posterior pubourethral ligament placation | Pereyra suspension | Negative postoperative cotton swab test (maximum straining angle <30 degrees) | 34/55 | 46/54 | 61.8 | 85.2 | 0.7 | 4 | 234
N = 109 | | | | | | | | (0.6; 0.9) | (3; 14) | (69; 363)A
6 month followup
Klarskov, 1986 ^778^ | Surgery: Burch colposuspension when patients had anterior suspension defect. Vaginal repair when patients had posterior bladder descent | Pelvic floor training program 5 times in weekly lessons guided by trained physiotherapists | Self-reported cure from urinary incontinence | 16/26 | 3/24 | 61.5 | 12.5 | 4.9 | 2 | 490
N = 40 | | | | | | | | (1.6; 14.8) | (1; 13) | (80; 1,726)E
4 month followup
Lalos, 1993 ^354^ | Retropubic urethrocystopexy | Pubococcygeal repair | Objective cure-negative pad test | 13/22 | 6/14 | 59.1 | 42.9 | 1.4
N = 36 | | | | | | | | (0.7; 2.8)
12 month followup
German, 1994 ^772^ | Modified needle suspension procedure | Vagina/obturator shelf procedure | Urinary continence | 15/26 | 17/24 | 57.7 | 70.8 | 0.8
N = 50 | | | | | | | | (0.5; 1.2)
24 month followup
Persson, 2000 ^356^ | Laparoscopic Burch colposuspension using one double-bite of polytetrafluoroethylene sutures | Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoroethylene sutures | Objective cure-negative pad test | 43/78 | 62/83 | 55.1 | 74.7 | 0.7 | 5 | 196
N = 161 | | | | | | | | (0.6; 0.9) | (3; 20) | (49; 312)A
12 month followup
Quadri, 1999 ^357^ | Burch colposuspension | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | Negative stress test | 8/15 | 14/15 | 53.3 | 93.3 | 0.6 | 3 | 400
N = 30 | | | | | | | | (0.3; 0.9) | (2; 16) | (61; 607)A
12 month followup
Costantini, 2007 ^321^ | Sacropexy combined with a Burch colposuspension | Colposacropexy, no prophylactic colposuspension | Urinary continence in those with MUCP>35cm/H2O | 17/34 | 20/32 | 50.0 | 62.5 | 0.8
N = 66 | | | | | | | | (0.5; 1.2)
40 month followup
Persson, 2002 ^770^ | Laparoscopic colposuspension | Tension-free vaginal tape by Ulmsten | Subjective cure: cured | 16/32 | 21/38 | 50.0 | 55.3 | 0.9
N = 76 | | | | | | | | (0.6; 1.4)
12 month followup
Colombo, 1997 ^486^ | Posterior pubourethral ligament placation | Pereyra suspension | Negative stress test | 24/55 | 37/54 | 44.0 | 68.0 | 0.6 | 4 | 240
N = 109 | | | | | | | | (0.4; 0.9) | (3; 15) | (375; 65)A
6 month followup
Persson, 2002 ^770^ | Laparoscopic colposuspension | Tension-free vaginal tape by Ulmsten | Subjective cure: much improved | 14/32 | 10/38 | 43.8 | 26.3 | 1.7
N = 76 | | | | | | | | (0.9; 3.2)
12 month followup
Ankardal, 2004 ^776^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | No leakage, no bother | 52/120 | 26/120 | 43.3 | 21.7 | 2.0 | 5 | 217
N = 240 | | | | | | | | (1.3; 3.0) | (2; 13) | (75; 428)E
12 month followup | | | No leakage, no bother (visual analog scale) | 33/120 | 18/120 | 41.8 | 34.0 | 1.2
| | | | | | | | (0.8; 1.9)
Albo, 2007 ^343^ | Burch colposuspension | Pubovaginal sling, using autologous rectus fascia | No symptoms of urinary incontinence, an increase <15g in pad weight during a 24-hour pad test, no incontinence episodes recorded in a 3-day diary, a negative stress test and not treatment for any urinary incontinence | 141/329 | 187/326 | 42.9 | 57.4 | 0.7 | 7 | 145
N = 655 | | | | | | | | (0.6; 0.9) | (5; 14) | (73; 207)A
24 month followup
Kitchener, 2006 ^771^ | Laparoscopic colposuspension | Open abdominal retropubic colposuspension | Subjective cure | 60/147 | 48/144 | 40.8 | 33.3 | 1.2
N = 291 | | | | | | | | (0.9; 1.7)
24 month followup
Colombo, 1997 ^486^ | Posterior pubourethral ligament placation | Pereyra suspension | Objective continence | 20/55 | 25/54 | 36.4 | 46.3 | 0.8
N = 109 | | | | | | | | (0.5; 1.2)
6 month followup
Persson, 2002 ^770^ | Laparoscopic colposuspension | Tension-free vaginal tape by Ulmsten | Objective cure: improved | 4/32 | 2/38 | 12.5 | 5.3 | 2.4
N = 79 | | | | | | | | (0.5; 12.1)
12 month followup
Bump, 1996 ^487^ | Needle colposuspension | Bladder neck endopelvic fascia plication | Genuine stress incontinence 6 months after operation | 2/16 | 1/16 | 12.5 | 6.3 | 2.0
N = 36 | | | | | | | | (0.2; 19.9)
6 month followup
Costantini, 2007 ^321^ | Sacropexy combined with a Burch colposuspension | Colposacropexy, no prophylactic colposuspension | Urinary continence in those with - MUCP <35cm/H_2_O | 4/34 | 8/32 | 11.8 | 25.0 | 0.5
N = 66 | | | | | | | | (0.2; 1.4)
40 month followup
Zullo, 2002 ^773^ | Transperitoneal laparoscopic retropubic urethropexy using nonabsorbable sutures | Transperitoneal laparoscopic retropubic urethropexy using polypropylene mesh fixed with tacks or staples | Objective cure as no leakage during cough and Valsalva maneuvre in standing position with bladder filled to maximum cystometric capacity during multichannel urodynamic exam. | 3/30 | 7/30 | 10.0 | 23.3 | 0.4
N = 60 | | | | | | | | (0.1; 1.5)
12 month followup
Ross, 1996 ^777^ | Laparoscopic Burch procedure with sutures for bladder neck elevation | Laparoscopic Burch procedure with mesh and staples for bladder neck elevation | Objective cure as negative stress test | 3/35 | 2/34 | 8.6 | 5.9 | 1.5
N = 69 | | | | | | | | (0.3; 8.2)
12 month followup
Zullo, 2002 ^773^ | Transperitoneal laparoscopic retropubic urethropexy using nonabsorbable sutures | Transperitoneal laparoscopic retropubic urethropexy using polypropylene mesh fixed with tacks or staples | Subjective cure as self-reported continence in visual analog scale (0=dry sensation, 10=severe leakage). | 2/30 | 4/30 | 6.7 | 13.3 | 0.5
N = 60 | | | | | | | | (0.1; 2.5)
12 month followup
Persson, 2002 ^770^ | Laparoscopic colposuspension | Tension-free vaginal tape by Ulmsten | Subjective cure: little improved | 1/32 | 3/38 | 3.1 | 7.9 | 0.4
N = 79 | | | | | | | | (0.0; 3.6)
12 month followup

Bold - significant differences in outcomes at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

##### Improvement in UI

Improvement in self-reported UI and the pad weight test was reported in 12 RCTs (Appendix Table F132). ^346,^ ^347,^ ^354^ – ^356,^ ^766^ – ^768,^ ^771,^ ^775,^ ^776,^ ^778^ One RCT reported improvement in more than 80 percent of women after laparoscopic colposuspension and Burch open colposuspension. ^346^ No significant relative benefit was detected when different treatments were compared.

##### Incidence of UI

The incidence of UI was 3.8 times higher after sacropexy combined with a Burch colposuspension compared to sacropexy alone (RR 3.8, 95 percent CI 1.2; 12.1) in continent women with advanced prolapse and a negative stress test before and after prolapse reduction (Appendix Table F133). ^321^ Another RCT demonstrated the opposite association with a lower incidence of stress UI after sacrocolpopexy with Burch colposuspension vs. sacrocolpopexy alone (RR 0.5, 95 percent CI 0.3; 0.7). ^761^ A large well-designed RCT also reported a significant reduction in severe stress UI after prophylactic surgery (RR 0.3, 95 percent CI 0.1; 0.5). ^761^ The sling procedure resulted in a significant reduction in stress UI 2 years after surgery compared to the Burch procedure in 665 women with predominant stress UI. ^343^

#### Surrogate outcomes

##### Subjective measures of UI

Burch retropubic urethropexy decreased the frequency of incontinent episodes and pad use compared to modified anterior colporrhaphy (Appendix Table F134). ^353^ Three RCTs reported improvement in quality of life after Burch colposuspension compared to other treatments. ^353,^ ^761,^ ^765^ The comparative effectiveness of different surgical procedures was not consistent in direction and effect size.

##### Objective measures of UI

Inconsistent differences in urodynamic outcomes with less than 10 percent of control levels were reported in all RCTs (Appendix Table F135).

#### Possible predictors of better effect

The trials used stratified randomization by a surgeon ^761^ and by participating centers ^343,^ ^771,^ ^779^ to estimate valid treatment effects independent of provider differences. Patient age, previous bladder neck surgery, ^771^ and concomitant rectocele repair for symptomatic rectocele ^779^ were balanced between treatment groups with stratified randomization to avoid effect measure modification. One trial reported the incidence of UI after sarcopexy combined with a Burch colposuspension compared to colposacropexy without prophylactic colposuspension in subgroups with baseline maximum urethral closure pressure above and below 35cmH_2_O. ^321^ No evidence suggested a significant effect modification by patient baseline conditions.

We analyzed the comparative effectiveness of different surgical procedures on urinary continenc e in females (Table 55). The laparoscopic Burch procedure with sutures did not provide significant benefit compared to staples. ^361,^ ^777^ The laparoscopic Burch procedure compared to open Burch surgery resulted in higher continence rates in one RCT, lower in another, and random differences in three RCTs. Sling procedures were compared to Burch colposuspension with significant relative benefit of continence in one RCT and random differences in four RCTs. The Burch procedure compared to the tension-free tape procedure did not result in higher cure rates in four RCTs. An increase in continence was observed after the Burch procedure compared to colporrhaphy in two RCTs. One RCT reported higher continence rates after Burch operation vs. retropubic urethropexy with random differences in two other RCTs. No significant differences in cure were observed in two RCTs that compared retropubic urethrocystopexy and pelvic floor repair. Tension-free tape procedures resulted in a very small relative benefit in continence compared to the sling procedure in five RCTs, while six RCTs reported random differences.

Table 55 Comparative effectiveness of surgical procedures on urinary continence in females (results from RCTs)

Author | Continence | Relative Risk (95%CI)
Sample
Burch Colposuspension vs. Abdominal Paravaginal Defect Repair
Colombo, 1996(224) | U | 1.37 (1.02; 1.84)
N = 36
12 month followup
Burch Colposuspension vs. Anterior Colporrhaphy
Bergman, 1989(179) | U | 1.40 (1.08; 1.81)
N = 127
12 month followup
Bergman, 1995(180) | U | 2.26 (1.33; 3.84)
N = 127
60 month followup
Kammerer-Doak, 1999(178) | U | 2.69 (1.27; 5.72)
N = 35 | SR | 5.05 (1.81; 14.09)
12 month followup
Colombo, 2000(181) | U | 1.71 (1.08; 2.68)
N = 71 | SR | 1.62 (1.12; 2.35)
168 month followup
Burch Colposuspension vs. Sling Procedures
Sand, 2000(228) | SR | 0.95 (0.82; 1.10)
N = 36 | U | 0.90 (0.75; 1.08)
3 month followup
Bai, 2005(229) | SR | 0.95 (0.80; 1.11)
N = 92
12 month followup
Culligan, 2003(82) | U+PT | 0.85 (0.68; 1.05)
N = 36
73 month followup
Demirci, 2001(230) | SR | 1.07 (0.71; 1.60)
N = 46
12 month followup
Albo, 2007(88) | SR+U+PT | 0.75 (0.64; 0.87)
N = 655
24 month followup
Burch Colposuspension vs. TVT
Bai, 2005(229) | SR | 1.01 (0.84; 1.21)
N = 92
12 month followup
Liapis, 2002(196) | PD | 1.03 (0.84; 1.26)
N = 71
24 month followup
El-Barky, 2005(200) | SR | 1.00 (0.71; 1.41)
N = 50
6 month followup
Wang, 2003(197) | U | 0.78 (0.60; 1.00)
N = 98 | PT | 0.80 (0.67; 0.97)
12 month followup | SR | 0.87 (0.67; 1.12)
Laparoscopic Burch Colposuspension vs. TVT
Persson, 2002(174) | U | 0.97 (0.80; 1.18)
N = 79 | SR | 0.90 (0.58; 1.42)
12 month followup
Ustun, 2003(84) | SR+U | 1.00 (0.77; 1.30)
N = 46
18 month followup
Valpas, 2004(158) | PT | 0.81 (0.62; 1.05)
N = 128 | U | 0.66 (0.51; 0.85)
12 month followup
Burch Colposuspension vs. Urethropexy
Colombo, 1994(192) | SR | 1.09 (0.93; 1.27)
N = 80 | U | 1.23 (0.93; 1.62)
36 month followup
Quadri, 1999(226) | U | 0.81 (0.61; 1.06)
N = 30 | SR | 0.68 (0.47; 0.98)
12 month followup | U | 0.57 (0.35; 0.93)
Laparoscopic Burch Colposuspension vs. Burch Colposuspension
Kitchener, 2006(201) | PT | 1.17 (0.98; 1.40)
N = 291 | SR | 1.22 (0.91; 1.66)
24 month followup
Su, 1997(231) | U | 0.84 (0.72; 0.98)
N = 92
12 month followup
Fatthy, 2001(83) | U | 1.00 (0.83; 1.21)
N = 74
18 month followup
Cheon, 2003(175) | U | 0.99 (0.83; 1.17)
N = 90
12 month followup
Sling vs. TVT Procedures
Arunkalaivanan, 2003(153) | SR | 1.05 (0.92; 1.19)
N = 142
12 month followup
Rechberger, 2003(154) | SR | 0.91 (0.76; 1.08)
N = 100
14 month followup
Abdel-Fattah, 2004(159) | SR | 0.97 (0.81; 1.16)
N = 142
36 month followup
Lim, 2005(161) | SR | 0.93 (0.79; 1.09)
N = 195
12 month followup
Andonian, 2005(162) | PT | 0.87 (0.75; 1.01)
N = 84
12 month followup
Tseng, 2005(163) | PT | 0.93 (0.74; 1.15)
N = 62
24 month followup
Wadie, 2005(165) | U | 0.99 (0.85; 1.16)
N = 53
0.5 month followup
Meschia, 2006(85) | SR+U | 0.85 (0.73; 0.99)
N = 190 | U | 0.82 (0.70; 0.97)
24 month followup | PT | 0.81 (0.68; 0.96)
Lord, 2006(167) | U | 1.00 (0.96; 1.04)
N = 313 | SR | 0.88 (0.79; 0.98)
1.5 month followup

Bold- significant differences in outcomes at 95% confidence level;

PT - negative pad test; U - urodynamic continence; SR - Self reported continence

We estimated that different surgical procedures may result in a large number of avoided stress and total UI in women with no consistent benefit of one procedure over others (Tables 56–58).

Table 56 Comparative effectiveness of surgical interventions on urinary continence in females (secondary prevention)

Author | Active Treatment | Control Treatment | Number Continent After Active Treatment/ Number Randomized | Number Continent After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of Attributable Events/1,000 Treated (95% CI)
Sample
Followup
Continence in Patients with Stress UI
Meshcia, 2004 ^330^ | Tension-free vaginal tape | Plication of the endopelvic fascia | 23/25 | 14/25 | 92.00 | 56.00 | 1.64 (1.14; 2.37) | 3 (1; 13) | 360 (78; 767)E
N = 50
100% female
6 month followup
Valpas, 2004 ^331^ | Tension-free vaginal tape under local anesthesia with polypropylene mesh tape placed under the midurethra | Laparoscopic mesh colposuspension under general anesthesia (Hannah and Chin) | 60/70 | 29/51 | 85.71 | 56.86 | 1.51 (1.17; 1.95) | 3 (2; 11) | 289 (94; 540)E
N = 128
100% female
12 month followup
Lord, 2006 ^341^ | Tension-free vaginal tape | Suprapubic urethral support sling | 134/154 | 122/159 | 87.10 | 76.50 | 1.13 (1.02; 1.26) | 9 (5; 63) | 106 (16; 199)E
N = 313
100% female
1.5 month followup
Meschia, 2006 ^340^ | Tension-free vaginal tape under local or epidural anesthesia | Intravaginal slingplasty under local or epidural anesthesia | 80/95 | 68/95 | 84.21 | 71.58 | 1.18 (1.01; 1.37) | 8 (4; 159) | 126 (6; 266)E
N = 190
100% female
24 month followup
Colombo, 1997 ^486^ | Posterior pubourethral ligament placation | Pereyra suspension | 24/55 | 37/54 | 44.00 | 68.00 | 0.64 (0.45; 0.90) | 4 (3; 15) | 240 (65; 375)A
N = 109
100% female
6 month followup
Klarskov, 1986 ^778^ | Surgery: Burch colposuspension when patients had anterior suspension defect. Vaginal repair when patients had posterior bladder descent | Pelvic floor training program 5 times/week, lessons guided by trained physiotherapists | 16/26 | 3/24 | 61.54 | 12.50 | 4.92 (1.64; 14.81) | 2 (1; 13) | 490 (80; 1,726)E
N = 40
100% female
4 month followup
Colombo, 1996 ^348^ | Burch colposuspension with placement of two couples of permanent polybutylate-coated polyester sutures | Abdominal paravaginal defect repair with 5–7 pairs of permanent braided silicone-coated polyester suture | 18/18 | 13/18 | 100.00 | 72.22 | 1.37 (1.02; 1.84) | 4 (2; 73) | 278 (14; 609)E
N = 36
100% female
6 month followup
Su, 1997 ^359^ | Laparoscopic colposuspension | Open Burch colposuspension | 37/46 | 44/46 | 80.40 | 95.60 | 0.84 (0.72; 0.98) | 7 (4; 59) | 152 (17; 268)A
N = 92
100 % female
12 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | 26/37 | 14/34 | 70.27 | 41.18 | 1.71 (1.08; 2.68) | 3 (1; 291) | 291 (35; 694)E
N = 71
100% female
12 month followup
Quadri, 1999 ^357^ | Burch colposuspension | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control. | 10/15 | 15/15 | 66.67 | 100.00 | 0.68 (0.47; 0.98) | 3 (2; 42) | 333 (24; 530)A
N = 30 | | Outcome: subjective cure
100% female | | Outcome: negative stress test | 8 | 14 | 53.33 | 93.33 | 0.57 (0.35; 0.93) | 3 (2; 16) | 400 (607; 61)A
12 month followup
Bergman, 1995 ^774^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | 27/38 | 11/35 | 71.05 | 31.43 | 2.26 (1.33; 3.84) | 3 (1; 10) | 396 (104; 893)E
N = 127 | Burch urethropexy | Modified Pereyra needle urethropexy | 27/38 | 13/35 | 71.05 | 37.14 | 1.91 (1.19; 3.08) | 3 (1; 14) | 339 (70; 773)E
100 % female
60 month followup
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | 18/19 | 3/16 | 94.74 | 18.75 | 5.05 (1.81; 14.09) | 1 (0; 7) | 760 (152; 2,454)E
N = 35 | | Outcome: subjective cure as no self-reported urinary incontinence
100% female | | Outcome: objective cure negative cough and Valsalva test in the supine and standing positions | 16/19 | 5/16 | 84.21 | 31.25 | 2.69 (1.27; 5.72) | 2 (1; 12) | 530 (84; 1,475)E
12 month followup
Bergman, 1989 ^345^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | 35/38 | 23/35 | 91.00 | 65.00 | 1.40 (1.08; 1.81) | 4 (2; 182) | 260 (55; 528)E
N = 127 | | Modified Pereyra needle urethropexy | 35/38 | 24/35 | 91.00 | 72.00 | 1.30 (1.03; 1.65) | 5 (2; 46) | 190 (22; 470)E
100% female
12 month followup
Persson, 2000 ^356^ | Laparoscopic Burch colposuspension using one double-bite of polytetrafluoroethylene sutures | Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoro-ethylene sutures | 43/78 | 62/83 | 55.13 | 74.70 | 0.74 (0.58; 0.93) | 5 (3; 20) | 196 (49; 312)A
N = 161 | | Outcome: objective cure - negative pad test
100% female | | Outcome: subjective cure | 50/78 | 72/83 | 64.10 | 86.75 | 0.74 (0.61; 0.89) | 4 (3; 10) | 226 (95; 335)A
12 month followup
Albo, 2007 ^343^ | Burch colposuspension | Pubovaginal sling, using autologous rectus fascia | 141/329 | 187/326 | 42.86 | 57.36 | 0.75 (0.64; 0.87) | 7 (5; 14) | 145 (73; 207)A
N = 655
100% female
24 month followup
Continence in Patents with any UI
Meschia, 2006 ^340^ | Tension-free vaginal tape under local or epidural anesthesia | Intravaginal slingplasty under local or epidural anesthesia | 78/95 | 63/95 | 82.11 | 66.32 | 1.24 (1.04; 1.47) | 6 (3; 35) | 158 (29; 311)E
N = 190
100% female
24 month followup
Maher, 2005 ^337^ | Pubovaginal sling | Transurethral Macroplastique | 2/22 | 17/23 | 9.09 | 73.91 | 0.12 (0.03; 0.47) | 2 9 (1; 3) | 648 (715; 391)A
N = 45
100% female
60 month followup
Colombo, 1997 ^486^ | Posterior pubourethral ligament placation | Pereyra suspension | 34/55 | 46/54 | 61.82 | 85.19 | 0.73 (0.57; 0.92) | 4 (3; 14) | 234 (69; 363)A
N = 109
100% female
6 month followup
Osman, 2003 ^769^ | Burch retropubic suspension or Pubovaginal sling | Oxybutynin hydrochloride 5mg 3 times/day | 40/50 | 0/25 | 80.00 | 0.00 | 41.29 (2.64; 645.03) | 1 | 800E
N = 75
100% female
12 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy. | 24/37 | 7/34 | 64.86 | 20.59 | 3.15 (1.56; 6.35) | 2 (1; 9) | 443 (116; 1,102)E
N = 71 | | Outcome: negative cotton swab test
100% female | | Outcome: subjective cure as no incontinence episodes | 30/37 | 17/34 | 81.08 | 50.00 | 1.62 (1.12; 2.35) | 3 (1; 17) | 311 (60; 674)E
12 month followup
Ankardal, 2004 ^776^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples. | 85/120 | 64/120 | 70.83 | 53.33 | 1.33 (1.08; 1.63) | 6 (3; 22) | 175 (45; 334)E
N = 240 | | Outcome: subjectively dry
100% female | | Outcome: no leakage, no bother | 52/120 | 26/120 | 43.33 | 21.67 | 2.00 (1.34; 2.97) | 5 (2; 13) | 217 (75; 428)E
12 month followup
Albo, 2007 ^343^ | Burch colposuspension | Pubovaginal sling, using autologous rectus fascia | 94/329 | 140/326 | 28.57 | 42.94 | 0.67 (0.54; 0.82) | 7 (5; 13) | 144 (76; 198)A
N = 655
100% female
24 month followup

Bold - significant differences in outcomes at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

Table 57 Comparative effectiveness of surgical interventions on improvement of urinary continence in adults

Author | Active Treatment | Control Treatment | Number Improved After Active Treatment/ Number Randomized | Number Improved After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of Attributable Events/1,000 Treated (95% CI)
Sample
Followup
Improvement in Stress UI
Dietz, 2005 ^760^ | Suprapubic arc sling | Intravaginal sling | 42/47 | 35/45 | 95.45 | 77.78 | 1.23 (1.04; 1.45) | 6 (3; 35) | 177 (28; 352)E
N = 196
100% female
23 month followup
Klarskov, 1986 ^778^ | Surgery: Burch colposuspension when patients had anterior suspension defect. Vaginal repair when patients had posterior bladder descent | Pelvic floor training program 5 times in weekly lessons guided by trained physiotherapists | 7/26 | 14/24 | 26.92 | 58.33 | 0.46 (0.23; 0.95) | 3 (2; 32) | 314 (452; 31)A
N = 40
100% female
4 month followup
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | 15/19 | 6/16 | 78.95 | 37.50 | 2.11 (1.07; 4.13) | 2 (1; 36) | 414 (27; 1,174)E
N = 35
100% female
12 month followup
Persson, 2000 ^356^ | Laparoscopic Burch colposuspension using one double-bite of polytetrafluoroethylene sutures | Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoroethylene sutures Outcome: Improved pad test | 20/78 | 9/83 | 25.64 | 10.84 | 2.36 (1.15; 4.87) | 7 (2; 63) | 148 (16; 420)E
N = 161 | | Outcome: subjective improvement | 25/78 | 6/83 | 32.05 | 7.23 | 4.43 (1.92; 10.23) | 4 (1; 15) | 248 (67; 667)E
100% female
12 month followup
Improvement in Any UI
Colombo, 1996 ^322^ | Cystopexy alone | Cystopexy with posterior pubourethral ligaments plication | 23/54 | 40/53 | 42.59 | 75.47 | 0.56 (0.40; 0.80) | 3 (2; 7) | 329 (453; 153)A
N = 107
100% female
24 month followup
Imamoglu, 2005 ^785^ | Macroplastique injection (polydimethylslioxane elastomer implants as the solute component and hydrogel as the carrier) of 5–7.5cc above or around the striated sphincter region of the urethra submucosally | Artificial urethral sphincter implantation | 3/13 | 8/11 | 23.10 | 72.70 | 0.32 (0.11; 0.91) | 2 (2; 16) | 496 (64; 647)A
N = 24
0% female
60 month followup
Akakura, 1999 ^789^ | Radical prostatectomy with pelvic lymph node dissection with 300mg of diethylstilbestrol diphosphate/day 8 weeks before surgery or radiation, and continued thereafter | External beam radiation by linear accelerator with 40 to 50Gy to the whole pelvis and a 20Gy boost to the prostatic area and with 300mg of diethylstilbestrol diphosphate/day 8 weeks before surgery or radiation, and continued thereafter | 22/56 | 0/44 | 40.00 | 0 | 35.53 (2.21; 569.82) | 3 | 390E
N = 100
0 % female
58.5 month followup
Ankardal, 2005 ^775^ | Open Burch colposuspension using sutures | Laparoscopic colposuspension using mesh and staples. Outcome: leakage <8g/24 hours at 48-hour pad test | 56/79 | 51/53 | 70.89 | 96.23 | 0.74 (0.63; 0.86) | 4 (3; 7) | 253 (138; 353)A
N = 211 | | Outcome: Improvement in Visual analog scale | 24/79 | 41/53 | 30.38 | 77.36 | 0.39 (0.27; 0.57) | 2 (2; 3) | 470 (336; 563)A
100% female
12 month followup
Ankardal, 2004 ^776^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | 37/120 | 62/120 | 30.83 | 51.67 | 0.60 (0.43; 0.82) | 5 (3; 11) | 208 (92; 293)A
N = 240
100% female
12 month followup
Improvement in Urge UI
Lim, 2005 ^334^ | Suburethral slingplasty with the Suprapubic Arc Sling macroporous monofilament threads | Suburethral slingplasty with the Intravaginal sling multifilament threads. | 23/58 | 32/54 | 39.66 | 59.26 | 0.67 (0.45; 0.99) | 5 (3; 115) | 196 (323; 9)A
N = 195 | | Outcome: free of symptoms of urge UI
100% female | | Outcome: improved but not cured urge UI | 23/58 | 8/54 | 39.66 | 14.81 | 2.68 (1.31; 5.47) | 4 (2; 22) | 248 (46; 662)E
12 month followup | Suburethral slingplasty with the tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with the Intravaginal sling multifilament threads | 22/58 | 9/54 | 37.93 | 16.67 | 2.28 (1.15; 4.50) | 5 (2; 40) | 213 (25; 583)E

Bold - significant differences in outcomes at 95% confidence level

Number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

Table 58 Comparative effectiveness of surgical interventions on urinary continence in adults

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of Attributable Events/1,000 Treated (95% CI)
Sample
Followup
Outcome - Stress UI
Meshcia, 2004 ^330^ | Tension-free vaginal tape | Plication of the endopelvic fascia | 1/25 | 9/25 | 4.00 | 36.00 | 0.11 (0.02; 0.81) | 3 (3; 15) | 320 (355; 67)A
N = 50
100% female
6 month followup
Brubaker, 2006 ^761^ | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone. Outcome: stress incontinence | 35/157 | 67/165 | 23.80 | 44.10 | 0.55 (0.39; 0.78) | 5 (4; 10) | 203 (99; 270)A
N = 322 | | Outcome: symptoms of stress incontinence | 29/157 | 60/165 | 19.00 | 39.70 | 0.51 (0.35; 0.75) | 5 (4; 10) | 207 (100; 260)A
100% female
3 month followup
Gallucci, 1998 ^793^ | Transurethral resection of the prostate | Transurethral electro vaporization of the prostate | 0/80 | 13/70 | 0.10 | 18.60 | 0.03 (0.00; 0.54) | 5 (5; 12) | 185 (86; 186)A
N = 150
0% female
12 month followup
Osman, 2003 ^769^ | Burch retropubic suspension or Pubovaginal sling | Oxybutynin hydrochloride 5mg 3 times/day | 1/50 | 12/25 | 2.00 | 48.00 | 0.04 (0.01; 0.30) | 2 (2; 3) | 460 (335; 477)A
N = 75
100% female
12 month followup
Costantini, 2007 ^321^ | Sacropexy combined with a Burch colposuspension | Colposacropexy, no prophylactic colposuspension | 9/34 | 1/32 | 26.47 | 3.13 | 8.47 (1.14; 63.14) | 4 (1; 235) | 233 (4; 1,942)E
N = 66
100% female
40 month followup
Outcome - Any UI
Costantini, 2007 ^321^ | Sacropexy combined with a Burch colposuspension | Colposacropexy, no prophylactic colposuspension | 12/34 | 3/32 | 35.29 | 9.38 | 3.76 (1.17; 12.12) | 4 (1; 63) | 259 (16; 1,043)E
N = 66
100% female
40 month followup
Albo, 2007 ^343^ | Burch colposuspension | Pubovaginal sling, using autologous rectus fascia | 319/329 | 280/326 | 97.00 | 86.00 | 1.13 (1.08; 1.18) | 9 (6; 15) | 110 (65; 159)E
N = 655 | | Outcome: Voiding with residual volume <100m
100% female | | Outcome: voiding dysfunction | 7/329 | 46/326 | 2.00 | 14.00 | 0.15 (0.07; 0.33) | 8 (8; 11) | 120 (130; 94)A
24 month followup
Risk of Urge UI
Zullo, 2005 ^490^ | Tension-free vaginal tape procedure plus postoperative vaginal estrogen 1 estrogen ovule (1mg/day) for 1 month, then 2 ovules once weekly for 5 months | Tension-free vaginal tape procedure alone | 1/28 | 8/28 | 4.00 | 29.00 | 0.13 (0.02; 0.93) | 4 (4; 53) | 250 (285; 19)A
N = 59
100% female
6 month followup

Bold - significant differences in outcomes at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

#### Summary

In conclusion, a large body of evidence suggests that surgical procedures of stress UI in women result in continence and improvement in UI in more than 75 percent of treated women. Different surgical procedures have comparable effectiveness with no differences in incident urge incontinence. The absolute risk of de novo urgency and urge incontinence after surgery for stress UI requires an RCT, powered to estimate the balance between benefits and harms in continent women with prolapse and patients with stress incontinence. The comparative effectiveness of behavioral interventions and surgery are not known. Individual patient factors that may modify the effects of different procedures also require future research.

### Reducing the Adverse Effects of Clinical Interventions Done for Other Purposes

#### Effects of clinical interventions on UI in adults with adenocarcinoma of the rectum

One large RCT of 1,861 patients with histologically confirmed adenocarcinoma of the rectum compared the effects of surgery and adjuvant radiotherapy on UI (Appendix Table F136). The incidence of UI and incontinence that required pad use was the same among patients after total mesorectal excision and adjuvant radiotherapy before surgery (Appendix Table F137).

#### Effects of clinical interventions on UI in males with urological diseases

Eleven RCTs examined clinical interventions to prevent UI in patients with prostate cancer ^780^ – ^790^ and three RCTs included patients with benign prostate diseases ^489,^ ^791^ – ^793^ (Appendix Table F138).

##### Patient outcome - Continence

Urinary continence was reported in four RCTs. ^782,^ ^783,^ ^785^ The highest rate of urinary continence (>92 percent) was reported after radical retropubic prostatectomy with bladder neck preservation (Appendix Table F139). ^783^

Artificial urethral sphincter implantation and macroplastique injection in the sphincter region of the urethra resulted in continence in 80 percent and 91 percent of patients with minimal baseline incontinence, respectively. ^785^ The rates of “social continence” were lower and differed substantially depending on baseline incontinence. ^785^ Only one RCT reported continence (77 percent) after combined therapy of prostate cancer. ^782^ No evidence showed a significant relative benefit of continence between compared interventions.

##### Patient outcome - Incidence of UI

The highest rates of UI were reported in one RCT that examined the effects of bladder neck mucosal eversion during retropubic radical prostatectomy (Appendix Table F140).

Almost all patients with benign prostate diseases were continent after transurethral resection of the prostate with the thick vapor resection loop ^792^ and transurethral resection of the prostate. ^793^ In contrast, Holmium laser enucleation resulted in 50 percent of UI in the same population of men with bladder outflow obstruction secondary to benign prostatic hyperplasia. ^489^

Patients with prostate cancer reported different rates of UI depending on the type and definition. Retropubic radical prostatectomy and vesico-urethral anastomosis with and without bladder neck eversion resulted in UI in more than 90 percent of patients. ^781^ The highest rate of urge UI (44 percent) was shown after radiation therapy with a four-field box technique to a dose of 70Gy. ^780^ The same treatment resulted in only 7 percent of self-reported stress UI in this trial. ^780^ The lowest incidence of UI among patients with prostate cancer was reported after supplemental beam radiation with I-125 (144Gy) (1 percent). ^784^

Indirect comparisons showed inconsistent relative risks of UI after surgical treatments and radiotherapy. The largest relative differences were observed in the risk of transient stress incontinence after transurethral resection of the prostate compared electro vaporization in patients with benign hypertrophy of prostate (0.1 percent vs. 18.6 percent respectively. ^793^ The rates of UI were substantially higher after adjuvant hormone therapy and surgery (300mg of diethylstilbestrol diphosphate/day) compared to adjuvant hormone therapy and external beam radiation (RR 35.5, 95 percent CI 2.2; 569.3). Patients with total baseline incontinence for >6 months after radical retropubic prostatectomy, transvesical prostatectomy, or transurethral prostatectomy reported cure more often after macroplastique injection to the sphincter region of the urethra compared to artificial urethral sphincter implantation (RR 0.3, 95 percent CI 0.1; 0.9. ^785^ Pad utilization was higher after radiotherapy compared to active surveillance (RR 8.3, 95 percent CI 1.1; 62.6). ^790^

##### Surrogate outcome - Subjective measures of quality of life

Few RCTs examined the effects of clinical interventions on quality of life specific for UI (Appendix Table F141). ^489,^ ^784,^ ^790,^ ^791^ Two regimens of radiotherapy resulted in different urinary scores of the American Urologic Association and Radiation Therapy Oncology Group criteria (mean difference 11.0, 95 percent CI 9.5; 12.5). ^784^ Bother from urinary difficulties was greater after transurethral resection of prostate compared to watchful waiting (mean difference 0.7 on a scale of 100 for least impairment, 95 percent CI 0.5; 0.9) in patients with benign prostate hypertrophy. ^791^ No differences in quality of life were seen in patients with prostate cancer after radiotherapy compared to active surveillance. ^790^

##### Surrogate outcome - Objective measures of UI

No differences in urodynamic outcomes were reported after different treatments of benign prostate diseases (Appendix Table F142). ^489,^ ^791,^ ^793^

##### Summary

In conclusion, some limited evidence suggests that UI as a secondary outcome related to both baseline diseases and treatments is more severe after surgery and radiotherapy compared to active surveillance. The baseline level of incontinence may modify the effects of the treatments. Bladder preservation surgical techniques did not provide consistent and significant benefit on UI. No consistent evidence across RCTs suggests that different treatments for prostate cancer and benign hyperplasia can provide better long-term outcomes. The reproducibility of large relative differences in outcomes in several RCTs requires future confirmation.

#### Effects of hormone therapy on UI in community dwelling women

The effects of systemic oral hormone therapy on continence status in postmenopausal women were examined in 19 RCTs (Appendix Table F143). ^352,^ ^365^ – ^367,^ ^369,^ ^513,^ ^794^ – ^806^ The effects of transdermal and intravaginal estrogen therapy to improve continence status in postmenopausal women were administered in 10 RCTs (Appendix Table F144). ^363,^ ^364,^ ^368,^ ^370,^ ^490,^ ^807^ – ^811^

##### Patient outcome - Continence

The preventive effects of systemic hormone replacement therapy in postmenopausal women were examined in several large RCTs (Appendix Table F145). ^797,^ ^801,^ ^806^ Only two RCTs reported positive significant effects of oral hormone therapy compared to baseline levels or placebo. ^364,^ ^797^ The administration of 2mg 17β-oestradiol combined with either 2.5, 5, 10, or 15mg dydrogesterone, orally once a day for 6 months cured incontinence in 23 percent of healthy postmenopausal nonhysterectomized women (RR 47.0, 95 percent CI 2.9; 763.5). ^797^ Oral hormone administration was less effective in achieving continence compared to local estrogen therapy (RR 0.4, 95 percent CI 0.3; 0.6). ^368^

Urinary continence was reported in RCTs that examined the curative effects of local therapy among incontinent women. ^364,^ ^368^ – ^370^ The highest rates of continence were reported after transdermal administration of an estrogen patch (100 percent) and gel 1.25g/day (90 percent) among postmenopausal women with self-reported urinary symptoms (Appendix Table F145). ^368^ Local estrogen in vagitories or jelly combined with physiotherapy and electrostimulation cured 22 percent of women 50–74 years of age with regular mild incontinence (>2 leakage episodes per month) compared to 0 percent after no hormone treatment (RR 20.7, 95 percent CI 1.2; 346.5). ^364^

##### Patient outcome - Improvement of UI

Several RCTs reported improvement in UI after local and oral hormone use ^363,^ ^364,^ ^794,^ ^797,^ ^798,^ ^802,^ ^806,^ ^808^ with the rates varying from 7 percent ^794^ to 68 percent, ^363^ depending on the route of the administration and the definition of the improvement (Appendix Table F146). The highest rate of improvement (68 percent) was reported after 6 months of intravaginal estrogen administration in incontinent postmenopausal women. ^363^ Combined estrogen and progesterone therapy cured nocturia, one of the risk factors of UI, in 65 percent of women. ^797^ Self-reported improvement in incontinence symptoms occurred in 45 percent of women after combined therapy of estrogen with alpha-adrenoreceptor agonist and in 40 percent after estrogen alone. ^802^

The combination of local estrogen administration with physiotherapy and electrostimulation reduced the frequency of wet episodes in 39 percent of incontinent women. ^364^

Hormone therapy improved UI compared to placebo treatments, but the effects were not consistent across RCTs. Intravaginal estrogen administration resulted in cure or improvement four times more often compared to placebo suppositories (RR 4.3, 95 percent CI 2.1; 8.7). ^363^ The same relative effect was reported after the combination of intravaginal estrogen with electrical stimulation (RR 4.3, 95 percent CI 1.5; 11.9). ^364^ In contrast, only one RCT showed a greater reduction in the number of incontinent episodes after placebo vs. ultra low dose of transdermal estrogen (RR 0.7, 95 percent CI .5; 0.9). ^808^

##### Patient outcome - UI

The investigations that were designed to evaluate protective effects of hormone therapy on postmenopausal UI reported either random differences or relative increase in UI after estrogen therapy compared to placebo controls (Appendix Table F147). ^363,^ ^365^ – ^367,^ ^513,^ ^794^ – ^796,^ ^798,^ ^801,^ ^806,^ ^808,^ ^809^ Only one RCT showed a reduction in subjective complaints of stress UI after intravaginal estrogen administration (RR 0.4, 95 percent CI 0.2; 0.6). ^363^ The majority of RCTs demonstrated a consistent significant relative increase in UI across different routes of administration and definitions of UI. Incident mixed UI was increased by 50 percent (RR1.5, 95 percent CI 1.1; 2.2) and incident stress UI by 80 percent (RR 1.8, 95 percent CI 1.6; 2.2) after estrogen therapy. ^365^ Incident urge UI increased by 30 percent and total UI by 40 percent (RR 1.4, 95 percent CI 1.3; 1.6) after estrogen combined with progestin (RR 1.3, 95 percent CI 1.2; 1.5). ^366^ Oral estrogen alone without progestin increased incident stress UI by 210 percent (RR 2.1, 95 percent CI 1.7; 2.5) ^365^ and worsened UI by 530 percent (RR 5.3, 95 percent CI 1.2; 23.5). ^367^

##### Patient outcome - Subjective progression of UI

Several RCTs obtained self-reported changes in severity after hormone therapy ^364,^ ^367,^ ^794,^ ^796,^ ^801,^ ^808^ and did not demonstrate differences compared to placebo (Appendix Table F148). One RCT reported a reduction in worsening of UI after transdermal estrogen (RR 0.2, 95 percent CI 0.1; 0.6). ^808^

##### Surrogate outcome - Subjective measures of severity of UI

No differences were found after hormone therapy compared to placebo treatments (Appendix Table F149). ^369,^ ^794,^ ^800,^ ^801,^ ^803,^ ^805,^ ^807^ One RCT reported an increase in daily incontinence episodes after estrogen (mean difference 0.9, 95 percent CI 0.3; 1.4). ^801^

##### Surrogate outcome - Objective measures of severity

There were no differences compared to controls or demonstrated small inconsistent changes (Appendix Table F150).

##### Summary

In conclusion, consistent evidence suggests that system hormone therapy increased the risk and progression of UI in postmenopausal females (Table 59). The relative harm varied from 42 to 106 percent for stress UI, 129 to 906 percent for any, and differed substantially for trials that measured urge UI.

Table 59 Comparative effectiveness of hormone therapy compared to placebo on risk of UI in females

Author | Active Treatment | Number of Cases After Active Treatment/ Number Randomized | Number of Cases After Control Treatment/ Number Randomized | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of Attributable Events/1,000 Treated (95% CI)
Sample
Followup
Systemic Hormone Therapy
Jackson, 1999 ^801^ | Post oestradiol valerate 2mg/day | 24/33 | 16/34 | 73.00 | 47.00 | 1.55 (1.02; 2.34) | 4 (2; 95) | 260 (10; 628)E
N = 67
6 month followup
Steinauer, ^366^ | Oral conjugated estrogen (0.625mg) and medroxy progesterone acetate (2.5mg) in 1 pill/day | 322/597 | 232/611 | 54.00 | 38.00 | 1.42 (1.25; 1.61) | 6 (4; 10) | 160 (96; 232)E
N = 1,208
50.4 month followup
Hendrix, 2005 ^365^ | 0.625mg of CEE plus 2.5mg of medroxyprogesterone acetate | 429/ 2675 | 218/ 2507 | 16.00 | 8.70 | 1.84 (1.58; 2.15) | 14 (10; 20) | 73 (51; 100)E
N = 5,182 | Estrogen alone: 0.625 mg of conjugated equine estrogen | 266/2675 | 131/2507 | 17.40 | 8.50 | 2.06 (1.69; 2.51) | 11 (8; 17) | 89 (59; 128)E
12 month followup | Outcome-incident Stress UI
| Outcome- incident mixed UI | 76/2675 | 50/2507 | 5.00 | 3.20 | 1.54 (1.09; 2.19) | 56 (26; 363) | 18 (3; 38)E
Steinauer, ^366^ | Oral conjugated estrogen (0.625mg) and medroxy progesterone acetate (2.5mg) in 1 pill/day | 382/597 | 302/611 | 64.00 | 49.00 | 1.29 (1.17; 1.43) | 7 (5; 12) | 150 (84; 211)E
N = 1,208
50.4 month followup
Goldstein, 2002 ^513^ | Levormeloxifene 0.5 mg/day | 338/978 | 37/970 | 17.00 | 4.00 | 9.06 (6.53; 12.57) | 8 (2; 5) | 130 (221; 463)E
N = 2,924
10 month followup
Steinauer, 2005 ^366^ | Oral conjugated estrogen (0.625mg) and medroxy progesterone acetate (2.5mg) in 1 pill/day | 287/597 | 220/611 | 48.00 | 36.00 | 1.34 (1.17; 1.53) | 8 (5; 17) | 120 (60; 190)E
N = 1,208
50.4 month followup
Hendrix, 2005 ^365^ | Estrogen plus progestin (E + P): 0.625mg CEE plus 2.5mg medroxyprogesterone acetate | | | | | 1.20 (1.06; 1.36)
N = 5,182 | Estrogen alone: 0.625mg conjugated equine estrogen | | | | | 1.59 (1.39; 1.82)
12 month followup
Goldstein, 2005 ^367^ | Conjugated equine estrogen 0.625mg/day | 11/152 | 2/152 | 7.00 | 1.30 | 5.29 (1.19; 23.48) | 18 (3; 400) | 57 (3; 292)E
N = 619
13 month followup
Non systemic Hormone Therapy
Dessole, 2004 ^363^ | Intravaginal estriol ovules: 1 ovule/day (1mg) for 2 weeks, then 2 ovules/week for 6 months | 14/44 | 37/44 | 31.82 | 84.09 | 0.38 (0.24; 0.59) | 2 (2; 3) | 523 (638; 341)A
N = 88
6 month followup
Lose, 2000 ^809^ | Oestradiol-releasing ring, 7.5mg oestradiol vs. estrogen pessaries 0.5mg every second day | 44/134 | 0/117 | 33.00 | | 77.79 (4.84; 1,249.40) | 3 | 330E
N = 251
6 month followup
Waetjen, 2005 ^808^ | 14mg transdermal E2/day for 2 years | 151/208 | 129/209 | 72.60 | 61.80 | 1.18 (1.03; 1.35) | 9 (5; 60) | 108 (17; 214)E
N = 417 | Unchanged stress incontinence
24 month followup | Unchanged incontinence | 116/208 | 94/209 | 56.00 | 44.90 | 1.24 (1.02; 1.50) | 9 (4; 98) | 111 (10; 226)E
| Unchanged urge incontinence | 178/208 | 162/209 | 85.70 | 77.30 | 1.10 (1.01; 1.21) | 12 (6; 182) | 84 (5; 163)E
| Worsened urge incontinence | 5/208 | 21/209 | 2.40 | 10.20 | 0.24 (0.09; 0.62) | 13 (11; 26) | 78 (39; 93)A
Holtedahl, 1998 ^364^ | Local estrogen in vagitories or jelly plus physiotherapy and electro stimulation | 10/36 | 27/44 | 28.00 | 61.00 | 0.45 (0.25; 0.81) | 3 (2; 8) | 330 (119; 455)A
N = 90
6 month followup

Bold - significant differences in outcomes at 95% confidence level;

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

Few RCTs demonstrated relative benefits of local estrogen administration for treatment of stress UI by 64 percent ^363^ and urge by 55 percent. ^364^

The effective clinical interventions that resulted in long-term stress urinary continence in more than 75 percent of participating females (Table 60) included Burch colposuspension techniques and sling and tension-free tape procedures. Total urinary continence in more than 75 percent of women was observed in several RCTs after tension-free tape and sling procedures (Table 60). The effective clinical interventions that resulted in long-term urinary continence in males with prostatic diseases included pelvic floor muscle training, electrical stimulation with biofeedback, radical retropubic prostatectomy with bladder neck preservation, and implantation of an artificial urethral sphincter (Table 61). Overall, consistent evidence from RCTs suggests that pelvic floor muscle training augmented with biofeedback, Burch colposuspension, and tension-free tape and sling procedures are effective to reduce the absolute risk of stress UI in women (Tables 62 and 63).

Table 60 Clinical interventions that resulted in stress urinary continence in more than 75% of participating females

Author | Treatment | Followup (months) | Rate (%) of Stress Urinary Continence
Sample
Bai, 2005 ^344^ | Burch colposuspension | 12 | 87.88
N = 92
Colombo, 1994 ^347^ | Burch colposuspension | 36 | 92.50
N = 80
Liapis, 2002 ^355^ | Burch colposuspension | 24 | 86.00
N= 71
Culligan, 2003 ^349^ | Burch colposuspension | 72.6 | 84.60
N = 36
Quadri, 1999 ^357^ | Burch colposuspension | 12 | 80.00
N = 30
Colombo, 1996 ^348^ | Burch colposuspension with placement of two couples of permanent polybutylate-coated polyester sutures | 12 | 100.00
N = 36
Sand, 2000 ^358^ | Burch procedures with four 2-0 polytetrafluoroethylene sutures and tension placed on the periurethral sutures (modified Tanagho method) | 3 | 94.74
N = 36
Gilja, 1998 ^351^ | Burch retropubic urethropexy | 37 | 92.86 (subjective continence)
N = 204 | | 39 | 89.29 (objective continence)
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | 12 | 94.74 (subjective continence)
N = 35 | | 12 | 84.21 (objective continence)
Bergman, 1989 ^345^ | Burch urethropexy | 12 | 91.00
N = 127
Fathy, 2001 ^350^ | Laparoscopic Burch colposuspension | 18 | 85.29 (subjective continence)
N = 74 | | 18 | 82.35 (objective continence)
Ustun, 2003 ^360^ | Laparoscopic Burch colposuspension | 18 | 82.60
N = 46
Persson, 2000 ^356^ | Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoroethylene sutures placed on each side of the urethra under transperitoneal video laparoscopy | 12 | 86.75
N = 161
Su, 1997 ^359^ | Open Burch colposuspension | 12 | 95.60
N = 92
Fathy, 2001 ^350^ | Open Burch colposuspension | 18 | 85.00 (subjective continence)
N = 74 | | 18 | 77.50 (objective continence)
Cheon, 2003 ^346^ | Open Burch colposuspension | 12 | 86.05
N = 90
Lalos, 1993 ^354^ | Retropubic urethrocystopexy | 13 | 77.27
N = 36
Zullo, 2001 ^361^ | Transperitoneal laparoscopic Burch procedure using nonabsorbable sutures | 12 | 93.33 (subjective continence)
N = 60 | | 12 | 90.00 (objective continence)
| Transperitoneal laparoscopic Burch procedure using Prolene mesh fixed with tacks or staples | 12 | 86.67 (subjective continence)
| | 12 | 76.67 (objective continence)
Gilja, 1998 ^351^ | Transvaginal Burch procedure | 36 | 90.91 (subjective continence)
N = 204 | | 38 | 86.36 (objective continence)
Ishiko, 2001 ^352^ | Combination of estriol (1mg/d) and pelvic floor muscle exercise | | 78.13
N = 73
Su, 1997 ^359^ | Laparoscopic colposuspension | 12 | 80.40
N = 92
Cheon, 2003 ^346^ | Laparoscopic colposuspension | 12 | 85.11
N = 90
Quadri, 1999 ^357^ | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | 12 | 100.00 (subjective continence)
N = 30 | | 16 | 93.33 (objective continence)
Colombo, 1994 ^347^ | Modified Marshall-Marchetti-Krantz urethropexy | 36 | 85
N = 80
Choe, 2000 ^323^ | Transvaginal antimicrobial mesh synthetic mesh | 6 | 95.00
N = 40
Gilja, 1998 ^351^ | Modified bladder neck suspension by Raz | 36 | 84.78 (subjective continence)
N = 204 | | 38 | 80.43 (objective continence)
Berglund, 1996 ^768^ | Pubococcygeal repair | 12 | 80.00
N = 45
Lalos, 1993 ^354^ | Pubococcygeal repair | 13 | 78.57
N = 36
Cholhan, 2004 ^333^ | Conventional sub urethral sling | 3 | 92.00
N = 48
Wadie, 2005 ^338^ | Fascial sling with free ends of flap fixed by a 1-zero polyglactin suture and the sling is fixed to the underlying periurethral fascia using 4-zero polyglactin sutures | 0.5 | 92.00
N = 53
Cholhan, 2004 ^333^ | Modified sling placed at the mid-urethra without tension | 3 | 89.00
N = 48
Abdel-Fattah, 2004 ^332^ | Pelvic pubovaginal sling | 36 | 75.68
N = 142
Arunkalaivanan, 2003 ^326^ | Porcine dermal sling (pelvic implant) by Barrington | 12 | 89.19
N = 142
Kuo, 2001 ^324^ | Pubovaginal sling procedure using polypropylene mesh | 6 | 100.00
N = 50
| Pubovaginal sling procedure using rectus fascia | 6 | 95.80
Bai, 2005 ^344^ | Pubovaginal sling using autologous rectus muscle fascia | 12 | 92.86
N = 92
David-Montefiore, 2006 ^339^ | Retropubic sub urethral sling procedure | 1 | 92.86
N = 88
Culligan, 2003 ^349^ | Sub urethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension | 72.6 | 100.00
N = 36
Sand, 2000 ^358^ | Sub urethral sling with continuous polytetrafluororthylene strip from rectus fascia into retropubic space and beneath urethra at urethrovesical junction level | 3 | 100.00
N = 36
Lim, 2005 ^334^ | Sub urethral slingoplasty with the intravaginal sling multifilament threads | 12 | 87.04 (subjective continence)
N = 195 | | 12 | 81.48 (objective continence)
| Sub urethral slingoplasty with the suprapubic arc sling macroporous monofilament threads | 12 | 77.59
| Sub urethral slingoplasty with the tension-free vaginal tape macroporous monofilament threads | 12 | 87.93 (subjective continence)
| | 12 | 82.76( objective continence)
Tseng, 2005 ^336^ | Suprapubic arch sling procedure | 24 | 80.65
N = 62
Andonian, 2005 ^335^ | Suprapubic arch sling procedure | 12 | 83.00
N = 84
Lord, 2006 ^341^ | Suprapubic urethral support sling | 1.5 | 76.50
N = 313
David-Montefiore, 2006 ^339^ | Transobturator suburethral sling procedure | 1 | 93.48
N = 88
deTayrac, 2004 ^329^ | Transobturator suburethral tape | 12 | 86.67
N = 61
Laurikainen, 2007 ^491^ | Transobturator tension-free vaginal polypropylene tape procedure by de Leval | 2 | 94.70
N = 273
Rechberger, 2003 ^327^ | Monofilament tape inserted at the midurethra using the tension-free vaginal tape delivery instrument | 13.5 | 88.00
N = 100
| Multifilament tape using the Intravaginal slingoplasty delivery instrument | 13.5 | 80.00
Laurikainen, 2007 ^491^ | Retropubic tension-free vaginal polypropylene tape procedure by Ulmsten | 2 | 98.53
N = 273
Wadie, 2005 ^338^ | Tension-free vaginal polypropylene tape | 0.5 | 92.86
N = 53
Meshcia, 2004 ^330^ | Tension-free vaginal tape procedure | | 92.00
N = 50
Bai, 2005 ^344^ | Tension-free vaginal tape procedure | 12 | 87.10
N = 92
Abdel-Fattah, 2004 ^332^ | Tension-free vaginal tape procedure | 36 | 77.94
N = 142
Lord, 2006 ^341^ | Tension-free vaginal tape procedure | 1.5 | 97.30 (Subjective continence)
N = 313 | | 1.5 | 87.10 (Objective continence)
Ustun, 2003 ^360^ | Tension-free vaginal tape procedure | 18 | 82.60
N = 46
Liapis, 2002 ^355^ | Tension-free vaginal tape procedure | 24 | 84.00
N = 71
deTayrac, 2004 ^329^ | Tension-free vaginal tape procedure | 12 | 90.00
N = 61
Wang, 2003 ^767^ | Tension-free vaginal tape procedure | 12 | 81.63
N = 98
Adamiak, 2002 ^325^ | Tension-free vaginal tape with spinal analgesia ( 0.5% bupivacaine hydrochloride administered at L_3_–L_4_ or L_4_–L_5_ interspace) | 6 | 97.14
N = 103
Adnonian, 2005 ^335^ | Tension-free vaginal tape by Ulmsten | 12 | 95.00
N = 84
Arunkalaivanan, 2003 ^326^ | Tension-free vaginal tape by Ulmsten | 12 | 85.29
N = 142
Tseng, 2005 ^336^ | Tension-free vaginal tape by Ulmsten | 24 | 87.10
N = 62
Meschia, 2006 ^340^ | Tension-free vaginal tape under local or epidural anesthesia | 24 | 84.21
N = 190
Valpas, 2004 ^331^ | Tension-free vaginal tape under local anesthesia with polypropylene mesh tape placed under the midurethra | 12 | 85.71
N = 128
Adamiak, 2002 ^325^ | Tension-free vaginal tape with local analgesia (injection of 0.5–0.75% lidocaine hydrochloride in subcutaneous tissue) | 6 | 93.85
N = 103

Table 61 Clinical interventions that resulted in urinary continence in more than 75% of participating males

Author | Treatment | Followup (months) | Rate (%) of Urinary Continence
Sample
Bales, 2000 ^262^ | Pelvic muscle exercises without biofeedback | 6 | 96.00
N = 100 | Graded pelvic muscle exercise training with biofeedback 2 to 4 weeks before surgery 4 times/day until surgery and to resume exercises when the urethral catheter was removed following surgery radical retropubic prostatectomy | 6 | 88.00
Yokoyama, 2004 ^256^ | Extracorporeal magnetic innervation (ExMI) using Neocontrol system was used with 20 min treatment sessions, 2/week for 2 months. The frequency of the pulse field was 10 Hz for 10 min, followed by a second treatment at 50 Hz for 10 minutes | 6 | 91.70
N = 36 | Functional electrical stimulation (FES) using anal electrode and pulses of 20-Hz square waves at a 300-μs pulse duration were used for 15 minutes twice daily for 1 month after retropubic radical prostatectomy | 6 | 83.30
| Pelvic floor muscle exercises after retropubic radical prostatectomy | 6 | 83.30
Wille, 2003 ^255^ | Instructions after radical retropubic prostatectomy on electrical stimulation (ES) for 15 minutes twice daily and biofeedback (BFB) 15 minutes twice daily with stimulation time of 5 seconds, and contracting and relaxing time of 5 and 15 seconds | 12 | 90.50 (objective continence)
N = 139 | | 12 | 88.60 (subjective continence)
| Instructions after radical retropubic prostatectomy about postoperative pelvic muscle exercises | 12 | 88.00 (subjective continence)
| Instructions about postoperative after radical retropubic prostatectomy electrical stimulation (ES) for 15 minutes twice daily with frequency 27 Hz, biphasic pulse shape with 1-sec bursts, a 5-second pulse width and 2-second pulse trains | 12 | 81.00
| Instructions about postoperative after radical retropubic prostatectomy pelvic muscle exercises | 12 | 76.70
Deliveliotis, 2005 ^786^ | 10ml of betamethasone cream 0.1% was applied locally to both neurovascular bundles after radical retropubic prostatectomy | 12 | 93.00
N = 60 | Usual neurovascular bundles with no corticoid cream after radical retropubic prostatectomy | 12 | 90.00
Srougi, 2001 ^783^ | Radical retropubic prostatectomy with bladder neck preservation according to the technique described by Malizia | 6 | 96.77
N = 70 | Radical retropubic prostatectomy with bladder neck resection according to that of Walsh, et al. | 6 | 92.31
Imamoglu, 2005 ^785^ | Artificial urethral sphincter implantation after radical retropubic prostatectomy | 48 | 90.90
N = 21 | Macroplastique injection (polydimethylslioxane elastomer implants as the solute component and hydrogel as the carrier) of 5–7.5cc above or around the striated sphincter region of the urethra submucosally after radical retropubic prostatectomy | 48 | 80.00
Van Cangh, 1998 ^782^ | Radical prostatectomy alone | 24 | 83.00
N = 100 | 60Gy external radiotherapy with 18MV photon beams between 12 and 16 weeks after radical prostatectomy | 24 | 77.00

Bold - significant differences in outcomes at 95% confidence level

Table 62 Clinical interventions that resulted in urinary continence at 6 or more months of followup (results from RCTs sorted by treatments and rates of continence after active treatments [from highest to lowest])

Author | Active Treatment | Control Treatment | Continence | Cases (Active Treatment) [Control Treatment] | % Continent (Active Treatment) [Control Treatment] | Relative Risk | Number Needed to Treat to Benefit One Case of Continence | Number of Attributable Events/1,000 Treated
Sample | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Pelvic Floor Exercise
Bo, 2005 ^275^ | Intensive PEM under the supervision of physical therapist | Home exercise groups | SR | (13) | (60.00) | 4.02 | 2 | 430
N = 47; 100% female | | | | [4] | [17.00] | (1.54; 10.53) | (1; 11) | (91; 1,620)E
180 month followup
Mørkved, 2002 ^815^ | PEM individually supervised by a physical therapist and at home with BFB | PEM individually supervised by a physical therapist and at home without BFB | PT | (28) | (52.83) | 1.26
N = 103; 100% female | | | | [21] | [42.00] | (0.83; 1.90)
6 month followup | | | SR | (19) | (35.85) | 1.28
| | | | [14] | [28.00] | (0.72; 2.27)
Alewijnse, 2003 ^271^ | PEM with reminder and self-help guide | Bladder training and PEM | SR | (17) | (32.70) | 0.79
N = 129; 100% female | | | | [21] | [41.20] | (0.48; 1.32)
14 month followup
Bo, 2005 ^275^ | Intensive PEM under the supervision of physical therapist | Home exercise groups | SR | (6) | (28.57) | 1.86
N = 47; 100% female | | | | [4] | [15.38] | (0.60; 5.73)
180 month followup
Wells, 1991 ^725^ | PEM | Phenylpropanolamine hydrochloride (50 mg/ day- 50 mg 2 times/day) | SR | (22) | (27.00) | 1.85
N = 157; 100% female | | | | [11] | [14.00] | (0.96; 3.56)
6 month followup
Wyman, 1998 ^269^ | BT+PEM | BT | SR | (16) | (27.00) | 1.62
N = 204; 100% female | | | | [10] | [16.00] | (0.79; 3.32)
6 month followup
Janssen, 2001 ^286^ | Individual BT+PEM | Group BT+PEM | SR | (28) | (22.00) | 1.58 | 13 | 80
N = 530; 100% female | | | | [57] | [14.00] | (1.05; 2.36) | (5; 143) | (7; 191)E
12 month followup
Wyman, 1998 ^269^ | PEM with BFB | BT | SR | (13) | (20.00) | 1.28
N = 204; 100% female | | | | [10] | [16.00] | (0.60; 2.72)
6 month followup
Pelvic Floor Exercise in Males with Urological Diseases
Wille, 2003 ^255^ | Postoperative (after radical prostatectomy) PEM | Postoperative PEM+BFB, electrical stimulation | SR | (41) | (88.00) | 0.98
N = 139; 0% female | | | | [41] | [88.60] | (0.84; 1.14)
12 month followup
Bales, 2000 ^262^ | PEM with BFB 4 weeks before and after radical prostatectomy | PEM | SR | (44) | (88.00) | 0.92
N = 100; 0% female | | | | [48] | [96.00] | (0.82; 1.03)
6 month followup
Yokoyama, 2004 ^256^ | Functional electrical stimulation after retropubic radical prostatectomy | PEM | SR | (10) | (83.30) | 1.00
N = 36; 0% female | | | | [10] | [83.30] | (0.70; 1.43)
6 month followup
Wille, 2003 ^255^ | Postoperative (after radical prostatectomy) PEM | Postoperative PEM+BFB, electrical stimulation | SR | (37) | (81.00) | 0.90
N = 139; 0% female | | | | [41] | [88.60] | (0.76; 1.07)
12 month followup | | | PT | (36) | (76.70) | 0.84
| | | | [42] | [90.50] | (0.70; 1.01)
Behavioral Interventions in Pregnant Women
Meyer, 2001 ^249^ | PEM with BFB and electro stimulation | Usual care | SR | (10) | (19.00) | 10.98 | 6 | 170
N = 107; 100% female | | | | [1] | [2.00] | (1.46; 82.80) | (1; 110) | (9; 1,636)E
10 month followup
Electrical Stimulation
Bo, 1999 ^299^ | Electrical stimulation | Use of a continence guard | PT | (7) | (21.88) | 3.50
N = 122; 100% female | | | | [2] | [6.25] | (0.79; 15.58)
6 month followup
Smith, 1996 ^293^ | Anticholinergic propantheline bromide (7.5 to 45 mg 2–3 times/day) | Electrical stimulation | SR | (3) | (16.67) | 0.38
N = 57; 100% female | | | | [4] | [11.00] | (0.11; 1.33)
48 month followup
Bo, 1999 ^299^ | Electrical stimulation | Use of a continence guard | SR | (3) | (9.38) | 3.00
N = 122; 100% female | | | | [1] | [3.13] | (0.33; 27.33)
6 month followup
Neuromodulation
Schmidt, 1999 ^305^ | Implantation of multiprogrammable neurostimulator | Standard medical therapy | SR | (24) | (47.00) | 43.45 | 2 | 460
N = 98; 81% female | | | | [0] | [1.00] | (2.72; 695.03) | (0; 58) | (17; 6,940)E
5 month followup
Weil, 2000 ^306^ | Sacral root neuromodulation with an implantable impulse generator | Conservative management: medications or PEM | SR | (9) | (42.86) | 9.86 | 3 | 385
N = 44; 91% female | | | | [1] | [4.35] | (1.36; 71.36) | (0; 64) | (16; 3,059)E
6 month followup
Bulking Agents
Strasser, 2007 ^308^ | Transurethral ultrasonography-guided injections of autologous myoblasts and fibroblasts | Conventional endoscopic injections of collagen | SR | (38) | (90.48) | 9.50 | 1 | 810
N = 63; 100% female | | | | [2] | [9.52] | (2.53; 35.63) | (0; 7) | (146; 3,298)E
12 month followup
Bano, 2004 ^309^ | Peri or transurethral porcine dermal implant injection (Permacol) | Transurethral silicone injection (Macroplastique) | PT | (15) | (60.00) | 1.67
N = 50; 100% female | | | | [9] | [36.00] | (0.90; 3.08)
6 month followup
Corcos, 2005 ^307^ | Intraurethral collagen sub mucosal injection | Surgery (needle bladder neck suspensions, Burch, and slings) | PT | (34) | (51.52) | 0.93
N = 133; 100% female | | | | [37] | [55.22] | (0.68; 1.28)
13 month followup
Schulz, 2004 ^310^ | Periurethral route of injection of bulking agent-dextran copolymer | Transurethral route of injection of bulking agent-dextran copolymer | PT | (1) | (5.00) | 0.33
N = 40; 100% female | | | | [3] | [15.00] | (0.04; 2.94)
12 month followup
Devices
Bo, 1999 ^299^ | Vaginal cones of 20, 40, and 70g for 20 minutes/day | Use of a continence guard | PT | (4) | (13.79) | 2.21
N = 122; 100% female | | | | [2] | [6.25] | (0.44; 11.17)
6 month followup | | | SR | (2) | (6.90) | 2.21
| | | | [1] | [3.13] | (0.21; 23.08)

PT - negative pad test; SR - self-reported continence;

Bold - significant relative risk at 95% confidence level;

E - number of excessive events per 1,000 treated

Table 63 Surgical interventions that resulted in significant difference in urinary continence at 6 or more months of followup (results from RCTs)

Author | Active Treatment | Control Treatment | Continence | Cases (Active) [Control] Treatment | % Continent (Active) [Control] Treatment | Relative Risk | Number Needed to Treat to Benefit One Case of Continence | Number of Attributable Events/1,000 Treated
Sample | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Gynecologic Surgery
Kaya, 2004 ^319^ | Extrafascial total abdominal hysterectomy | Intrafascial total abdominal hysterectomy | SR | (4) | (8.89) | 0.29 | 5 | 222
N = 90; 100% female | | | | [14] | [31.11] | (0.10; 0.80) | (4; 16) | (62; 279)A
12 month followup
Surgery for Prolapse and UI
Colombo, 1996 ^348^ | Burch colposuspension | Abdominal paravaginal defect repair | U | (18) | (100.00) | 1.37 | 4 | 278
N = 36; 100% female | | | | [13] | [72.22] | (1.02; 1.84) | (2; 73) | (14; 609)E
12 month followup
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | SR | (18) | (94.74) | 5.05 | 1 | 760
N = 35; 100% female | | | | [3] | [18.75] | (1.81; 14.09) | (0; 7) | (152; 2,454)E
12 month followup
Meshcia, 2004 ^330^ | Tension-free vaginal tape | Plication of the endopelvic fascia | U | (23) | (92.00) | 1.64 | 3 | 360
N = 50; 100% female | | | | [14] | [56.00] | (1.14; 2.37) | (1; 13) | (78; 767)E
6 month followup
Bergman, 1989 ^345^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | U | (35) | (91.00) | 1.40 | 4 | 260
N = 127; 100% female | | | | [23] | [65.00] | (1.08; 1.81) | (2; 18) | (55; 528)E
12 month followup | | Modified Pereyra needle urethropexy | U | (35) | (91.00) | 1.30 | 5 | 190
| | | | [24] | [72.00] | (1.03; 1.65) | (2; 46) | (22; 470)E
Valpas, 2004 ^331^ | Tension-free vaginal tape under local anesthesia | Laparoscopic mesh colposuspension under general anesthesia | U | (60) | (85.71) | 1.51 | 3 | 289
N = 128; 100% female | | | | [29] | [56.86] | (1.17; 1.95) | (2; 11) | (94; 540)E
12 month followup
Meschia, 2006 ^340^ | Tension-free vaginal tape | Intravaginal slingplasty | SR+U | (80) | (84.21) | 1.18 | 8 | 126
N = 190; 100% female | | | | [68] | [71.58] | (1.01; 1.37) | (4; 159) | (6; 266)E
24 month followup
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | U | (16) | (84.21) | 2.69 | 2 | 530
N = 35; 100% female | | | | [5] | [31.25] | (1.27; 5.72) | (1; 12) | (84; 1,475)E
12 month followup
Meschia, 2006 ^340^ | Tension-free vaginal tape | Intravaginal slingplasty | U | (79) | (83.16) | 1.22 | 7 | 147
N = 190; 100% female | | | | [65] | [68.42] | (1.03; 1.43) | (3; 46) | (22; 295)E
24 month followup
Meschia, 2006 ^340^ | Tension-free vaginal tape | Intravaginal slingplasty | PT | (78) | (82.11) | 1.24 | 6 | 158
N = 190; 100% female | | | | [63] | [66.32] | (1.04; 1.47) | (3; 35) | (29; 311)E
24 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | SR | (30) | (81.08) | 1.62 | 3 | 311
N = 71; 100% female | | | | [17] | [50.00] | (1.12; 2.35) | (1; 17) | (60; 674)E
168 month followup
Osman, 2003 ^769^ | Burch retropubic suspension or pubovaginal sling | Oxybutynin hydrochloride 5 mg 3 times/day | SR | (40) | (80.00) | 41.29 | | 0
N = 75; 100% female | | | | [0] | [0.00] | (2.64; 645.03) | | (0; 217)E
6 month followup
Bergman, 1995 ^774^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | U | (27) | (71.05) | 2.26 | 3 | 396
N = 127; 100% female | | | | [11] | [31.43] | (1.33; 3.84) | (1; 10) | (104; 893)E
60 month followup | | Modified Pereyra needle urethropexy | U | (27) | (71.05) | 1.91 | 3 | 339
| | | | [13] | [37.14] | (1.19; 3.08) | (1; 14) | (70; 773)E
Ankardal, 2004 ^776^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | SR | (85) | (70.83) | 1.33 | 6 | 175
N = 240; 100% female | | | | [64] | [53.33] | (1.08; 1.63) | (3; 22) | (45; 334)E
12 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | U | (26) | (70.27) | 1.71 | 3 | 291
N = 71; 100% female | | | | [14] | [41.18] | (1.08; 2.68) | (1; 29) | (35; 694)E
168 month followup
Quadri, 1999 ^357^ | Burch colposuspensions | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | SR | (10) | (66.67) | 0.68 | 3 | 333
N = 30; 100% female | | | | [15] | [100.00] | (0.47; 0.98) | (2; 42) | (24; 530)A
15 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | CST | (24) | (64.86) | 3.15 | 2 | 443
N = 71; 100% female | | | | [7] | [20.59] | (1.56; 6.35) | (1; 9) | (116; 1, 102)E
168 month followup
Persson, 2000 ^356^ | Laparoscopic Burch colposuspension using one double-bite of sutures | Laparoscopic Burch colposuspension using two single-bite sutures of sutures | SR | (50) | (64.10) | 0.74 | 4 | 226
N = 161; 100% female | | | | [72] | [86.75] | (0.61; 0.89) | (3; 10) | (95; 335)A
12 month followup
Ward, 2004 ^816^ | Tension-free tape procedure | Colposuspension | PT | (111) | (63.43) | 1.25 | 8 | 125
N = 344; 100% female | | | | [86] | [50.89] | (1.03; 1.50) | (4; 56) | (18; 255)E
24 month followup
Colombo, 1997 ^486^ | Posterior pubourethral ligament plication | Pereyra suspension | CST | (34) | (61.82) | 0.73 | 4 | 234
N = 109; 100% female | | | | [46] | [85.19] | (0.57; 0.92) | (3; 14) | (69; 363)A
6 month followup
Persson, 2000 ^356^ | Laparoscopic Burch colposuspension using one double-bite of sutures | Laparoscopic Burch colposuspension using two single-bite sutures of sutures | PT | (43) | (55.13) | 0.74 | 5 | 196
N = 161; 100% female | | | | [62] | [74.70] | (0.58; 0.93) | (3; 20) | (49; 312)A
12 month followup
Quadri, 1999 ^357^ | Burch colposuspensions | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | U | (8) | (53.33) | 0.57 | 3 | 400
N = 30; 100% female | | | | [14] | [93.33] | (0.35; 0.93) | (2; 16) | (61; 607)A
16 month followup
Colombo, 1997 ^486^ | Posterior pubourethral ligament placation | Pereyra suspension | U | (24) | (44.00) | 0.64 | 4 | 240
N = 109; 100% female | | | | [37] | [68.00] | (0.45; 0.90) | (3; 15) | (65; 375)A
6 month followup
Ankardal, 2004 ^776^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | SR | (52) | (43.33) | 2.00 | 5 | 217
N = 240; 100% female | | | | [26] | [21.67] | (1.34; 2.97) | (2; 13) | (75; 428)E
12 month followup
Albo, 2007 ^343^ | Burch colposuspension | Pubovaginal sling, using autologous rectus fascia | SR+U+PT | (141) | (42.86) | 0.75 | 7 | 145
N = 655; 100% female | | | | [187] | [57.36] | (0.64; 0.87) | (5; 14) | (73; 207)A
24 month followup
Maher, 2005 ^337^ | Pubovaginal sling | Transurethral macroplastique | U | (2) | (9.09) | 0.12 | 2 | 648
N = 45; 100% female | | | | [17] | [73.91] | (0.03; 0.47) | (1; 3) | (391; 715)A
12 month followup

CST - negative cotton swab test; PT - negative pad test; U - urodynamic continence; SR - self-reported continence;

Bold - significant relative risk at 95% confidence level;

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

Tension-free tape and sling procedures decreased the absolute risk of total UI. No clinical interventions demonstrated consistent reduction in absolute risk of urge UI.

The largest relative benefits with more than 300 excessive cases of resolved stress incontinence were reported in RCTs per 1,000 females treated with pelvic floor muscle training, Burch colposuspensions, and tension-free vaginal tape compared to usual care or other treatments (Table 64). Few RCTs reported large relative benefits on total urinary continence in females with local estrogen, Burch colposuspension with abdominal hysterectomy, and pubovaginal sling. Few small RCTs reported more than 300 cases of resolved urge incontinence in males and females after electrical or magnetic stimulation.

Table 64 Clinical interventions that resulted in a larger number of attributable events of urinary continence in adults from the community (number of additional continence cases >300 per 1,000 treated)

Author | Active Treatment | Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Number of Attributable Events/1,000 Treated
Sample | | | | | (95% CI)
Followup
Stress Continence
Aksac, 2003 ^288^ | Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds) via biofeedback (vaginal probe in EMG pressure mode) 3 times/week | Usual care | 80.00 | 0.10 | 799
N = 50; 100% female | | | | | (0; 261)E
2 month followup
Bo, 1999 ^299^ | Pelvic floor exercise with 8–12 contractions 3 times/day and in groups with skilled physical therapists 1/week | Untreated control group offered the use of a continence guard | 48.28 | 3.13 | 452
N = 122; 100% female | | | | | (36; 3,415)E
6 month followup
Bo, 2005 ^275^ | Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months | Home exercise groups | 60.00 | 17.00 | 430
N = 47; 100% female | | | | | (91; 1,620)E
Acute
Kammerer-Doak, 1999 ^353^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | 94.74 | 18.75 | 760
N = 35; 100% female | | | | | (152; 2,454)E
12 month followup
Klarskov, 1986 ^778^ | Surgery: Burch colposuspension when patients had anterior suspension defect. Vaginal repair when patients had posterior bladder descent | Pelvic floor training program 5 times in weekly lessons guided by trained physiotherapists | 61.54 | 12.50 | 490
N = 40; 100% female | | | | | (80; 1,726)E
4 month followup
Bergman, 1995 ^774^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | 71.05 | 31.43 | 396
N = 127; 100% female | | | | | (104; 893)E
60 month followup | | Modified Pereyra needle urethropexy | 71.05 | 37.14 | 339
| | | | | (70; 773)E
Meshcia, 2004 ^330^ | Tension-free vaginal tape | Plication of the endopelvic fascia | 92.00 | 56.00 | 360
N = 50; 100% female | | | | | (78; 767)E
6 month followup
Quadri, 1999 ^357^ | Burch colposuspensions | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | 66.67 | 100.00 | 333
N = 30; 100% female | | | | | (24; 530)A
12 month followup
Urinary Continence
Akhila, 2006 ^368^ | Conjugated equine estrogen 0.625mg/day orally | Transdermal patch with 50mg/day estrogen | 40.00 | 100.00 | 600
N = 116; 100% female | | | | | (420; 708)A
12 month followup
Colombo, 2000 ^362^ | Burch colposuspension with abdominal hysterectomy | Anterior colporrhaphy with vaginal hysterectomy | 64.86 | 20.59 | 443
N = 71; 100% female | | | | | (116; 1,102)E
12 month followup
Maher, 2005 ^337^ | Pubovaginal sling | Transurethral Macroplastique | 9.09 | 73.91 | 648
N = 45; 100% female | | | | | (391; 715)A
60 month followup
Urge Continence
But, 2003 ^298^ | Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz. | Placebo treatment with sham inactive device | 79.00 | 22.00 | 570
N = 52; 100% female | | | | | (131; 1,488)E
2 month followup
Schmidt, 1999 ^305^ | Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place | Standard medical therapy | 47.00 | 1.00 | 460
N = 98; 81% female | | | | | (17; 6,940)E
5 month followup
Weil, 2000 ^306^ | Sacral root neuromodulation with an implantable impulse generator | Prior conservative management: medications or pelvic floor exercise | 42.86 | 4.35 | 385
N = 44; 91% female | | | | | (16; 3,059)E
6 month followup

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

#### Effects of pharmacological agents on UI

Three systematic Cochrane reviews reported UI after drug administration. The reviews analyzed randomized trials of anticholinergic drugs on overactive bladder, ^812^ of adrenergic drugs for urinary incontinence, ^813^ and of serotonin and noradrenaline reuptake inhibitors for stress UI in adults. ^642^ We estimated attributable events of cure, improvement, or progression from the RCTs published after 1990. Adrenergic drugs were better than placebo in two of five RCTs (Table 65). Continence rates after pelvic floor muscle exercise were comparable with rate after adrenergic drugs. A combination of phenylpropanolamine that was withdrawn from the market when it was linked to intracerebral hemorrhage with estrogen resulted in continence in 0–40 percent of women. No trials included males. Clenbuterol resulted in continence 2 to 4.6 times more often than placebo in two trials but was not more effective compared to pelvic floor muscle training.

Table 65 Effects of adrenergic drugs on self-reported urinary continence in females (results from RCTs) ^813^

Author* | Active Treatment | Control Treatment | Cases After (Active) [Control] Treatment | Rate (%) After (Active) [Control] Treatment | Relative Risk (95% CI) | Number Needed to Treat | Number of Attributable Events per 1,000 Treated
| | | | | | | (95% CI)
Yasuda, 1993 | Clenbuterol | Placebo | (8) | (2.27) | 4.57 | 12 | 81
| | | [2] | [10.39] | (1.00; 20.88) | | (0; 452)E
Lose, 1988 | Norepinephrine | Placebo | (6) | (14.29) | 1.83 | 8 | 118E
| | | [3] | [26.09] | (0.52; 6.39)
Hilton, 1990 | Phenylpropanolamine | Placebo | (0) | (18.18) | 0.24 | 6 | 182A
| | | [2] | [0.00] | (0.01; 4.44)
Lehtonen, 1986 | Phenylpropanolamine | Placebo | (15) | (36.36) | 1.96 | 3 | 351
| | | [8] | [71.43] | (1.06; 3.63) | | (22; 958)E
Yasuda, 1993 | Clenbuterol | Placebo | (36) | (23.86) | 1.96 | 4 | 229
| | | [21] | [46.75] | (1.26; 3.05) | | (62; 489)E
Wells, 1991 | Phenylpropanolamine | PFMT | (54) | (51.22) | 1.41 | 5 | 208
| | | [42] | [72.00] | (1.09; 1.81) | | (46; 416)E
Ishiko, 2000 | Clenbuterol | PFMT | (10) | (52.63) | 1.27 | 7 | 140E
| | | [10] | [66.67] | (0.73; 2.21)
| | Clenbuterol + PFMT | (10) | (77.27) | 0.86 | 9 | 106A
| | | [17] | [66.67] | (0.56; 1.32)
Wells, 1991 | Phenylpropanolamine | PFMT | (2) | (26.47) | 0.15 | 4 | 226
| | | [9] | [3.85] | (0.03;, 0.63) | | (97; 256)A
| | | (22) | (47.06) | 0.90 | 21 | 48A
| | | [16] | [42.31] | (0.56; 1.45 )
Walter, 1990 | Phenylpropanolamine + estrogen | Estrogen | (2) | (14.29) | 0.93 | 105 | 10A
| | | [2] | [13.33] | (0.15; 5.76)
Hilton, 1990 | Phenylpropanolamine + estrogen | Estrogen | (13) | (15.79) | 2.84 | 3 | 290E
| | | [3] | [44.83] | (0.93; 8.65)
Walter, 1990 | Phenylpropanolamine + estrogen | Estrogen | (4) | (42.86) | 0.62 | 6 | 162A
| | | [6] | [26.67] | (0.22; 1.75)
Hilton, 1990 | Phenylpropanolamine + estrogen | Placebo | (13) | (18.18) | 2.47 | 4 | 266E
| | | [2] | [44.83] | (0.66; 9.20)
| | | (12) | (18.18) | 3.30 | 2 | 18E
| | | [2] | [60.00] | (0.90; 12.15)
| Phenylpropanolamine | Estrogen | (12) | (0.00) | 11.90 | 2 | 600E
| | | [0] | [60.00] | (0.78; 181.54)

* These studies were part of the systematic review;

PFMT- pelvic floor muscle training;

Bold - significant relative risk at 95% confidence level;

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

The Cochrane review of 61 trials of adults with overactive bladder syndrome that compared anticholinergic drugs with placebo treatment or no treatment reported the combined outcome of cure or improvement in UI from eight RCTs (Table 66). The other 53 RCTs did not report patient outcomes. No trials were conducted in men. Administration of propiverine (two RCTs) or extended release tolteradine (two RCTs) for 2–12 weeks resulted in greater rates of cure or improvement compared to placebo. Pooled analysis of six RCTs of different drugs resulted in 139 percent higher rates of cure of improvement (RR 1.4, 95 percent CI 1.3; 1.5). ^812^ The authors also reported significant reduction in daily leakage episodes (mean difference -0.5, 95 percent CI -0.7; -0.4) after drug administration.

Table 66 Effects of anticholinergic drugs compared to placebo on self-reported urinary continence or improvement in UI in adults with overactive bladder (results from RCTs) ^812^

Author* | Active Treatment | Cases After (Active) [Control] Treatment | Rate (%) After (Active) [Control] Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events per 1,000 Treated
| | | | (95% CI) | | (95% CI)
Abrams, 1998 | Tolterodine 2mg bid or oxybutynin 5mg tid | (117) | (47.37) | 1.05
| | [27] | [49.58] | (0.77; 1.42)
Burgio, 1998 | Oxybutynin 2.5–5mg tid | (45) | (65.38) | 1.25
| | [34] | [81.82] | (0.99; 1.58)
Dorschner, 2000 | Propiverine 15mg tid | (43) | (53.06) | 1.65 | 3 | 347
| | [26] | [87.76] | (1.25; 2.20) | | (130; 634)E
Freeman, 2003 | Tolteradine ER 4 mg once a day | (173) | (31.55) | 1.38 | 8 | 119
| | [118] | [43.47] | (1.14; 1.66) | | (45; 208)E
Halaska, 1994 | Propiverine 15mg tid | (34) | (47.37) | 1.89 | 2 | 421
| | [18] | [89.47] | (1.33; 2.69) | | (155; 799)E
Millard, 1999 | Tolterodine 1–2mg bid | (126) | (37.50) | 1.33
| | [24] | [50.00] | (0.95; 1.87)
Szonyi 1995 | Oxybutynin 2.5mg bid | (22) | (55.17) | 1.42
| | [16] | [78.57] | (0.97; 2.08)
VanKerrebroeck, 2001 | Tolterodine extended release 2–4mg qid | (313) | (42.83) | 1.42 | 6 | 181
| | [218] | [60.89] | (1.26; 1.61) | | (111; 260)E

* These studies were part of the systematic review;

Bold - significant relative risk at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

The review of eight RCTs of duloxetine administered for 3–12 weeks in patients with predominantly stress UI concluded that the drug failed to show better curative effects than placebo (Table 67). However, improvement rates and quality of life scores were better after active duloxetine compared to placebo. The long-term effects of pharmacological agents on UI are not clear. The effects on surrogates reported in many trials may not reflect patient outcomes. The comparative effectiveness of drugs compared to other conservative interventions remains unclear.

Table 67 Effects of serotonin and noradrenaline reuptake inhibitor duloxetine on stress UI (results from RCTs) ^642^

Author* | Daily Dose of Duloxetine | Control Treatment | Outcomes | Cases After (Active) [Control] Treatment | Rate (%) After (Active) [Control] Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events per 1,000 Treated
| | | | | | (95% CI) | | (95% CI)
Dmochowski, 2003 | 80mg | Placebo NT | Failure to cure | (308) | 94.10 | 0.95
| | | | [319] | 89.53 | (0.91; 1.00)
Millard, 2003 | 80mg | Placebo or NT | Failure to cure | (211) | 93.94 | 0.99
| | | | [217] | 92.95 | (0.94; 1.04)
Norton, 2002 | 80mg | Placebo or NT | Failure to cure | (100) | 84.85 | 0.96
| | | | [112] | 81.30 | (0.86; 1.07)
| 40mg | Placebo or NT | Failure to cure | (93) | 84.85 | 0.89
| | | | [112] | 75.61 | (0.79; 1.01)
| 20mg | Placebo or NT | Failure to cure | (107) | 84.85 | 0.99
| | | | [112] | 83.59 | (0.89; 1.09)
Cardozo, 2004 | 0mg | Placebo or NT | Failure to improve | (16) | 86.54 | 0.40 | 2 | 518
| | | | [45] | 34.78 | (0.27; 0.61) | | (341; 635)A
Dmochowski, 2003 | 80mg | Placebo or NT | Failure to improve | (167) | 66.37 | 0.73 | 6 | 178
| | | | [225] | 48.55 | (0.64; 0.84) | | (109; 239)A
Millard, 2003 | 80mg | Placebo or NT | Failure to improve | (92) | 43.29 | 0.94
| | | | [100] | 40.53 | (0.75; 1.16)
Van Kerrebroeck, 2004 | 80mg | Placebo or NT | Failure to improve | (119) | 66.40 | 0.73 | 5 | 182
| | | | [164] | 48.18 | (0.62; 0.85) | | (100; 252)A
Zinner, 1998 | 40mg | Placebo or NT | Failure to improve | (18) | 85.29 | 0.64 | 3 | 307
| | | | [29] | 54.55 | (0.45; 0.90) | | (86; 465)A
Mulcahy, 1996 | 20mg | Placebo or NT | Failure to improve | (13) | 51.35 | 0.46 | 4 | 277
| | | | [19] | 23.64 | (0.26; 0.81) | | (96; 380)A
Zinner, 1998 | 20mg | Placebo or NT | Failure to improve | (18) | 85.29 | 0.62 | 3 | 324
| | | | [29] | 52.94 | (0.44; 0.88) | | (104; 478)A
| 30mg | Placebo or NT | Failure to improve | (10) | 85.29 | 0;45 | 2 | 468
| | | | [29] | 38.46 | (0.27, 0.75) | | (215; 621)A
Norton, 2002 | 80mg | Placebo or NT | Failure to cure (objective - SPT) | (69) | 63.16 | 0.97
| | | | [72] | 61.06 | (0.79; 1.18)
| 40mg | Placebo or NT | Failure to cure (objective - SPT) | (63) | 63.16 | 0.90
| | | | [72] | 56.76 | (0.73; 1.11)
| 20mg | Placebo or NT | Failure to cure (objective - SPT) | (75) | 63.16 | 1.08
| | | | [72] | 68.18 | (0.89; 1.30)
| 80mg | Placebo or NT | Failure to cure (objective - CST) | (96) | 87.29 | 0.96
| | | | [103] | 84.21 | (0.87; 1.07)
| 40mg | Placebo or NT | Failure to cure (objective - SPT) | (86) | 87.29 | 0.88 | 10 | 105
| | | | [103] | 76.79 | (0.78; 0.99) | | (5; 194)A
| 20mg | Placebo or NT | Failure to cure (objective - CST) | (101) | 87.29 | 1.03
| | | | [103] | 90.18 | (0.94,;1.13)
Dmochowski, 2003 | 80mg | Placebo or NT | Failure to cure (objective - diary) | (308) | 94.10 | 0.95
| | | | [319] | 89.53 | (0.91; 1.00)
Millard, 2003 | 80mg | Placebo or NT | Failure to cure (objective - diary) | (211) | 93.94 | 0.99
| | | | [217] | 92.95 | (0.94; 1.04)
Norton, 2002 | 80mg | Placebo or NT | Failure to cure (objective - diary) | (100) | 84.85 | 0.96
| | | | [112] | 81.30 | (0.86; 1.07)
| 40mg | Placebo or NT | Failure to cure (objective - diary) | (93) | 84.85 | 0.89
| | | | [112] | 75.61 | (0.79; 1.01)
| 20mg | Placebo or NT | Failure to cure (objective - diary) | (107) | 84.85 | 0.99
| | | | [112] | 83.59 | (0.89; 1.09)
Cardozo, 2004 | 80mg | Placebo or NT | Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (17) | 7.69 | 4.33 | 4 | 256
| | | | [4] | 33.33 | (1.57; 12.00) | | (43; 846)E
Kinchen, 2005 | 80mg | Placebo or NT | Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (110) | 40.97 | 1.20
| | | | [93] | 49.11 | (0.98; 1.47)
Millard, 2003 | 80mg | Placebo or NT | Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (167) | 64.07 | 1.15
| | | | [148] | 73.57 | (1.01; 1.30)
Norton, 2002 | 80mg | Placebo or NT | Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (62) | 26.81 | 1.65 | 6 | 175
| | | | [37] | 44.29 | (1.18; 2.30) | | (49; 249)E
Van Kerrebroeck, 2004 | 80mg | Placebo or NT | Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (139) | 48.18 | 1.17
| | | | [119] | 56.28 | (0.99; 1.38)
Norton, 2002 | 40mg | Placebo or NT | Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (51) | 26.81 | 1.39
| | | | [37] | 37.23 | (0.98; 1.97)
| 20mg | Placebo or NT | Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (43) | 26.81 | 1.16
| | | | [37] | 31.16 | (0.80; 1.68)
| 80mg | Duloxetine 40 mg | Failure to cure (quantification of symptoms) | (100) | 75.61 | 1.08
| | | | [93] | 81.30 | (0.94; 1.23)
| 80mg | Duloxetine 20 mg | Failure to cure (quantification of symptoms) | (100) | 83.59 | 1.08
| | | | [107] | 81.30 | (0.94; 1.23)
| 80mg | Duloxetine 20 mg | Failure to cure (quantification of symptoms) | (100) | 83.59 | 0.97
| | | | [107] | 81.30 | (0.87; 1.09)
| 40mg | Duloxetine 20 mg | Failure to cure (quantification of symptoms) | (93) | 83.59 | 0.90
| | | | [107] | 75.61 | (0.80; 1.03)
Zinner, 1998 | 30mg | Duloxetine 20 mg | Failure to cure (quantification of symptoms) | (10) | 52.94 | 0.73
| | | | [18] | 38.46 | (0.41; 1.30)
| 40mg | Duloxetine 20 mg | Failure to cure (quantification of symptoms) | (18) | (52.94) | 1.03
| | | | [18] | [54.55] | (0.66; 1.61)
| 40mg | Duloxetine 30 mg | Failure to cure (quantification of symptoms) | (18) | (38.46) | 1.42
| | | | [10] | [54.55] | (0.80; 2.53)
Norton, 2002 | 80mg | Duloxetine 40 mg | Failure to cure (objective - SPT) | (6) | (56.76) | 1.08
| | | | [63] | [5.31] | (0.86; 1.34)
| 80mg | Duloxetine 20 mg | Failure to cure (objective - SPT) | (69) | (68.18) | 0.90
| | | | [75] | [61.06] | (0.74; 1.09)
| 40mg | Duloxetine 20 mg | Failure to cure (objective - SPT) | (63) | (68.18) | 0.83
| | | | [75] | [56.76] | (0.68; 1.02)
| 80mg | Duloxetine 40 mg | Failure to cure (objective - CST) | (96) | (76.79) | 1.10
| | | | [86] | [84.21] | (0.96; 1.25)
| 80mg | Duloxetine 20 mg | Failure to cure (objective - CST) | (96) | (90.18) | 0.93
| | | | [101] | [84.21] | (0.84; 1.03)
| 40mg | Duloxetine 20 mg | Failure to cure (objective - CST) | (86) | (90.18) | 0.85 | 7 | 134
| | | | [101] | [76.79] | (0.76; 0.96) | | (37; 220)A
| 80mg | Duloxetine 40 mg | Failure to cure (objective - diary) | (100) | (75.61) | 1.08
| | | | [93] | [81.30] | (0.94; 1.23)
| 80mg | Duloxetine 20 mg | Failure to cure (objective - diary) | (100) | (83.59) | 0.97
| | | | [107] | [81.30] | (0.87; 1.09)
| 40mg | Duloxetine 20 mg | Failure to cure (objective - diary) | (93) | (83.59) | 0.90
| | | | [107] | [75.61] | (0.80; 1.03)
| 80mg | Duloxetine 40 mg | General Health Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (62) | (37.23) | 1.19
| | | | [51] | [44.29] | (0.89; 1.58)
| 80mg | Duloxetine 20 mg | General Health Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (62) | (31.16) | 1.42 | 8 | 131
| | | | [43] | [44.29] | (1.04; 1.94) | | (-292; -13)E
| 40mg | Duloxetine 20 mg | General Health Status (‘very much better,’ ‘much better,’ or‘a little better’ from PGI-I) | (51) | (31.16) | 1.19
| | | | [43] | [37.23] | (0.86; 1.66)

* These studies were part of the systematic review;

Bold - significant relative risk at 95% confidence level;

NT- no treatment; SPT - stress pad test; PCT - positive cough stress test; PGI-I - Patient Global Impression of Improvement;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated

One multicenter RCT of 695 males 40 years or older with overactive bladder examined the effects of alpha 1 adrenoreceptor blocker tamsulosin for treatment of benign prostatic hyperplasia. ^814^ Men were treated with 0.4mg of tamsulosin, 4mg of tolterodine ER, both tolterodine ER plus tamsulosin, or placebo for 12 weeks. Urge incontinence rates were the same after tamsulosin (RR 1.1, 95 percent 0.8; 1.6), tolterodine (RR 1.1, 95 percent CI 0.8; 1.7), or the combinations of both drugs (RR 1.1, 95 percent CI 0.8; 1.6) compared to placebo.

##### Summary

Clenbuterol was more effective than a placebo in achieving continence in females with stress UI but not compared to pelvic floor muscle training. Extended release tolteradine for 2–12 weeks resulted in greater rates of cure or improvement compared to placebo in adults with overactive bladder syndrome. Duloxetin administered for 3–12 weeks in patients with predominantly stress UI improved UI, but the rates of continence did not differ from placebo. Long-term effects of medications combined with pelvic floor training on continence are unknown. Comparative effectiveness of combined treatments, including medication, requires future research.

### Effects of Clinical Interventions on FI

#### Baseline mechanisms of FI

comprise loss of structural and functional integrity of pudendal nerve activity, of pelvic floor muscles, of rectal compliance and of the anal sphincter and loss of rectal sensation. ^17,^ ^20,^ ^23,^ ^24^ Disposition of the rectum into the anus (rectal prolapse) or protrusion of the rectum through the vagina (rectocele) also can result in FI. Clinical types of FI include urge incontinence (discharge of feces despite active attempts to retain bowel contents), passive incontinence (involuntary discharge of stool or flatus without awareness), and fecal seepage (leakage of small amount of stool without awareness or staining of undergarments following an otherwise normal evacuation). The aim of effective clinical intervention is to restore the structure and function of these mechanisms, improve the strength and coordination between the pelvic floor and the anal sphincter muscles during voluntary squeeze and following rectal perception, enhance anorectal sensory perception and control, regulate pudendal nerve activity, and provide normal anatomical positioning of the rectum.

### Clinical Interventions to Reduce Progression of FI in Adults in Nursing Homes and LTC Settings

#### Conservative management of FI in nursing homes

Consistent benefits of combined nurse led interventions on the severity of incontinence were reported in three RCTs that examined the effects of conservative management of FI in nursing homes (Appendix Table F151). ^233^ – ^235^ The largest improvement (10 percent increase in appropriate toileting) was achieved after prompted voiding treatment, including checks for incontinence, offering toileting assistance, prompted voiding, and social reinforcement of appropriate toileting (Appendix Table F152). ^233^ The percentage of incontinent wet checks among total checks by nurses was reduced by 3 percent. ^233^ Integrated incontinence care and frequent exercises showed a significant reduction of 6 percent in the proportion of wet episodes. ^235^ Functional incidental training that included prompted voiding combined with individualized endurance and strength-training exercises reduced the number of wet stool checks among total checks by 1.2 percent. ^234^

#### Pharmacological interventions on FI in LTC settings

One RCT examined the effects of laxative agents in elderly patients with FI associated with chronic fecal impaction (Appendix Table F151). ^817^ The number of FI episodes per patient day did not differ when an osmotic agent with a rectal stimulant and weekly tap-water enemas were compared to single osmotic laxative (Appendix Table F153). ^817^

#### Evidence-based conservative management of FI

included the assessment of patient history and rectal examination, patient education on regular toilet habits, pelvic floor and sphincter-strengthening exercises, and individualized doses of laxatives. ^509^ Implementation of this program did not reduce the frequency of self-reported fecal episodes (Appendix Table F154) and did not improve quality of life (Appendix Table 155) in stroke patients with constipation and FI (Appendix Tables F156 and F157).

#### Summary

In conclusion, very few well-designed RCTs examined the clinical interventions on FI in nursing homes and LTC settings. A small improvement in severity of FI was reported after integrated care in nursing homes that included prompted toileting and exercise. The effects of conservative management of FI in subgroups by gender, race, and ethnicity remain unknown. Clinical interventions that can reduce the risk of incidence and progression of FI in LTC settings have not beet tested in RCTs.

### Dietary Interventions on FI in Community Dwelling Adults

One small placebo-controlled RCT examined the effects of fiber supplements on FI. A usual diet supplemented with 7.1g of soluble fiber psyllium reduced the rate of incontinent stools to 17 percent compared to 50 percent after placebo treatments, but the relative risk was not significant (RR 0.3, 95 percent CI 0.1; 1.2) (Appendix Table F158). ^371^

Supplementation with 25g of gum Arabic increased stool weight by 3 percent compared to placebo with no difference in water content and holding capacity (Appendix Table F159). The effects of dietary fiber on FI need future investigation in a large clinical trial.

### Effects of Conservative Management of Postnatal FI in Females

In an RCT of 747 women with postnatal UI (Appendix Table F151) ^251,^ ^252^ intensive pelvic floor muscle training reinforced by visiting nurses within 9 months after delivery significantly reduced the rate of any FI to 4.4 percent compared to 10.5 percent after standard care (RR 0.5, 95 percent CI 0.3; 1.0) at 1 year but not 6 years of followup (Appendix Table F159 and F160). However, severe FI did not differ between groups either at 1 or at 6 years.

#### Summary

The effects of behavioral changes supervised by health care providers that would provide long-term protection from postnatal FI require further investigation.

### Behavioral Interventions on FI in Females

Self-administered behavioral interventions in females were examined in three RCTs. ^250,^ ^372,^ ^511^

#### Patient outcomes

##### Continence

Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor muscle training produced continence twice as often in women with FI after obstetric and sphincter trauma as augmented biofeedback pelvic floor muscle training with audiovisual feedback and electric stimulation (RR 2.0, 95 percent CI 1.1; 3.9) (Appendix Table F161). ^372^ We estimated that 382 cases of FI would be prevented per 1,000 women with FI after obstetric and sphincter trauma treated with augmented biofeedback and electrostimulation (95 percent CI 27; 1,055). Pelvic floor muscle training with visual and verbal biofeedback therapy using a radial catheter with a latex balloon cured no more women with frequent idiopathic FI than pelvic floor muscle training (Appendix Table F162). ^511^

##### FI

In an RCT of 493 pregnant women with and 1,034 women without previous vaginal birth, self-administered perineal massage during pregnancy until delivery did not improve postnatal FI at 3 months postpartum (Appendix Table F163). ^250^

#### Surrogate outcome - Objectively measured mean maximum resting pressure

was increased by 5 percent and squeeze pressure by 3 percent compared to the control intervention (Appendix Table F164). ^372^

### Effects of Behavioral Interventions on FI in Community Dwelling Adults

The effects of behavioral interventions on FI in Community dwelling adults (secondary prevention) were examined in six RCTs ^373^ – ^376,^ ^502,^ ^818^ and one nonrandomized controlled trial ^501^ (Appendix Table F151).

#### Patient outcomes

##### Continence

Continence was reported in one large RCT of 171 patients with FI of different causes. ^376^ Bowel training with instructions on sphincter exercises with and without biofeedback was no better than standard care (Appendix Table F165).

##### Improvement of FI

A nonrandomized controlled clinical trial examined the effects of telephone-assisted biofeedback treatment for patients with refractory FI living in rural areas. ^501^ Improvement in self-reported Pascatori and St Mark scores and in anal manometry outcomes was not greater compared to the standard face-to-face protocol (Appendix Table F166). Rates of improvement in FI (45 to 55 percent) were the same after hospital-based computer-assisted sphincter pressure biofeedback with and without electrostimulation, as well as after receiving advice on diet, fluid intake, and bowel training (Appendix Table F167). ^376^ Education and biofeedback therapy using a radial catheter resulted in nonsignificant improvement in FI in 50 percent of patients with idiopathic FI. ^511^ Standard care combined with pelvic floor muscle training improved symptoms of FI in 45 percent of the patients. ^511^ Pelvic floor muscle training with manometry and ultrasound improved FI in 43 percent of the patients. ^501^

In conclusion, a few tested behavioral interventions cured 5 to 10 percent and improved FI in more than 40 percent of the patients but with no statistically significant differences compared to standard care.

##### FI

The effects of behavioral clinical interventions were examined on self-reported frequency of incontinent episodes and severity scores as well as on objective instrumental outcomes (Appendix Table F168). Progression of FI was three times more frequent after telephone-assisted biofeedback compared to individualized biofeedback. ^501^

#### Surrogate outcome - Subjectively measure severity of FI and quality of life with FI

Hospital-based training and biofeedback services combined with sphincter exercises and electromyelogram biofeedback devices significantly reduced the number of fecal accidents per week by 47 percent. ^376^ The same intervention without the device reduced fecal episodes by 52 percent. ^376^ In a small crossover RCT of 23 patients with idiopathic FI associated with abnormal perineal descent and frequent irritable bowel syndrome, pelvic floor muscle training with active sensory retraining reduced FI episodes by 37 percent compared to exercises with no instructions. ^373^ One RCT reported a significant reduction in weekly pad use for FI by 78 percent after hospital biofeedback in combination with an electromyelogram device, by 61 percent after hospital-based computer-assisted sphincter pressure biofeedback, and by 89 percent after lifestyle changes and sphincter exercises. ^376^

Behavioral interventions did not improve total FI scores in the majority of the trials. ^375,^ ^376,^ ^502,^ ^818^ Only one RCT reported a small significant improvement in St Mark FI scores by 9 percent. ^375^ One RCT showed significant improvement in quality of life after pelvic floor muscle training and biofeedback compared to baseline levels by 4 percent in Pescatori scores of family and relationship and by 16 percent in Pescatori scores of travel restriction. ^374^

#### Summary

In conclusion, four RCTs of behavioral treatments of FI reported small (<40 percent) improvement in severity and quality of life (Appendix Table F169). ^372^ – ^375^ Limited evidence suggested a significant reduction in FI after complex behavioral interventions, including lifestyle changes and exercises augmented with biofeedback (Appendix Table F170). ^376^

### Effects of Electrical Stimulation and Neuromodulation on FI

Several RCTs examined the effects of electrical stimulation or neuromodulation on FI (Appendix Table F151). ^377,^ ^819^ – ^821^

#### Patient outcomes

##### Continence

Active anal stimulation did not produce better cure (Appendix Table F171), significant, or small improvement in FI compared to sham stimulation (Appendix Table F172). ^819^

##### Improvement

Individualized sacral nerve continuous stimulation improved FI in 89 percent of patients with severe baseline FI compared to 17 percent after sham stimulation. ^377^ We estimated that 720 additional patients among 1,000 treated would experience an improvement in symptoms of FI after individualized sacral nerve stimulation.

#### Surrogate outcomes

##### Subjective measures of quality of life

However, the treatments did not improve quality of life with random differences after active and sham stimulation (Appendix Table F173). Electrical stimulation of the anal sphincter in addition to intra-anal EMG biofeedback did not change FI compared to standard training of the pelvic floor. ^821^ Active stimulation therapy using an anal plug with a pulse generator did not improve patient satisfaction with bowel habits of the incomplete evacuation score. ^820^

##### Objective measures of severity of FI

All RCTs reported small inconsistent differences in anal manometry outcomes after active stimulation compared to the control (Appendix Table F174).

#### Summary

In conclusion, electrical stimulation did not improve FI in the majority of the RCTs. The significant relative improvement after sacral nerve stimulation in patients with severe baseline FI requires future confirmation in a large well designed RCT with long-term followup.

### Effects of Massage on FI

One RCT did not show significant differences in risk of FI 3 months postpartum from massage and stretching of the perineum during the second stage of labor with a water soluble lubricant. ^514^

### Effects of Pharmacological Agents on FI in Community Dwelling Adults

Pharmacological agents on FI in community dwelling adults were examined in 12 RCTs (Appendix Table F151). ^378^ – ^380,^ ^403^ – ^405,^ ^822^ – ^827^

#### Botulinum toxin

##### Outcome - FI

Four RCTs examined the effects of botulinum toxin in patients with constipation and symptoms of outlet obstruction. ^380,^ ^822,^ ^826,^ ^827^ The incidence of FI was not significantly higher after Botox compared to lateral internal anal sphincterotomy. ^380^ All patients were continent after local injection of Botox to the each side of the puborectalis or to the posterior aspect of this muscle (Appendix Table F175). ^822^

##### Surrogate outcome - Subjective measures of severity of FI

Self-reported modified Wexner Fecal Continence scores ^826^ were not improved after Botox administration (Appendix Table F176).

##### Surrogate outcome - Objective measure of severity of FI

Anal manometry outcomes ^827^ were not improved after Botox administration (Appendix Table F176).

#### Loperamide

Two RCTs examined the effects of loperamide in patients after restorative proctocolectomy for ulcerative colitis ^378^ and in patients with chronic diarrhea and FI. ^823^

##### Surrogate outcome - Subjective measure of severity of UI

Neither treatment resulted in better outcomes. Frequency of FI episodes and use of pads at night were the same after loperamide or placebo (Appendix Table F177). ^378^ Loperamide reduced fecal urgency in patients with chronic diarrhea and FI (mean difference -1.0, 95 percent CI -1.9; -0.1) ^823^

##### Surrogate outcome - Objective measures of severity of FI

Loperamide in patients after restorative proctocolectomy for ulcerative colitis ^378^ and in patients with chronic diarrhea and FI ^823^ did not improve anal manometry outcomes ^378,^ ^823^ (Appendix Table F176).

Synthesizing the evidence from all available clinical trials, few interventions ^378^ – ^380^ resulted in fecal continence in more than 50 percent of patients but were not statistically better than placebo ^378,^ ^379^ or surgery ^380^ (Appendix Tables F178–F180). Chemical sphincterotomy with isosorbide-5-mononitrate, ^404^ glycerine trinitrate, and Botox resulted in 100 percent continence rate. ^405^ Chemical sphincterotomy with phenylephrine demonstrated significant efficacy compared to placebo. ^824^ Reproducibility of the significant effects of chemical sphincterotomy using different agents should be confirmed in the large RCTs.

### Effects of Chemical Sphincterotomy

Three RCTs analyzed the effects of chemical sphincterotomy (primary prevention) in patients with chronic anal fissure. ^403^ – ^405^

#### Patient outcomes - Continence

All patients were continent after rectal administration of isosorbide-5-mononitrate ^404^ and after glycerine trinitrate ointment ^405^ (Appendix Table F177). Healing of anal fissures was observed four times more often after isosorbide-5-mononitrate compared to placebo (RR 4, 95 percent CI 1; 13). ^404^ We estimated that rectal administration of isosorbide-5-mononitrate would result in 580 healed patients among 1,000 treated.

#### Surrogate outcome - Subjective and objective measures of severity of FI

Chemical sphincterotomy with oral nifedipine ^403^ or rectal administration of isosorbide-5-mononitrate ^404^ did not result in consistent improvement in the Wexner scores and anal manometry outcomes (Appendix Table F176).

### Effects of Alpha-Adrenergic Agonist on FI

#### Patient outcome - Improvement in FI

Topical 10 percent phenylephrine, alpha-adrenergic agonist increasing anal sphincter pressure, applied to the anus improved FI symptoms three times more often than placebo in patients with dysfunctional anal sphincter (RR 3, 95 percent CI 1; 13). ^824^

#### Surrogate outcome - Subjective measures of severity of FI

Anal administration of phenylephrine significantly improved FI scores and FI symptom scores ^503^ but not the Wexner scale scores ^824^ (Appendix Table F176).

### Effects of Nonabsorbable Basic Aluminum Salt on Late Rectal Injury Related to Radiotherapy

#### Patient outcome - FI

Oral sucralfate did not prevent FI in prostate cancer patients treated with radiotherapy at a 3 month followup. ^379^

### Effects of Medical Bowel Confinement on FI

#### Patient outcome - Improvement in FI

Medical bowel confinement and regular diet did not improve FI after anorectal reconstructive surgery at 13 months of followup. ^825^

#### Summary

Synthesizing the evidence from all available clinical trials, a few interventions ^378^ – ^380^ resulted in fecal continence in more than 50 percent of patients but were not statistically better than placebo ^378,^ ^379^ or surgery ^380^ (Appendix Tables F158 and F159s). Chemical sphincterotomy with isosorbide-5-mononitrate, ^404^ glycerine trinitrate, and Botox resulted in 100 percent continence rate. ^405^ Administration of phenylephrine to improve sphincter function in patients with FI after ileoanal pouch construction demonstrated significant efficacy compared to placebo. ^824^ Reproducibility of the significant effects of chemical sphincterotomy using different agents should be confirmed in the large RCTs.

### Effects of Different Techniques to Repair External Anal Sphincter after Acute Obstetric Trauma

Four RCTs compared end-to-end technique to overlapping repair of obstetric anal sphincter lacerations (Appendix Table F151). ^381^ – ^384^

#### Patient outcome - FI

Defects of internal or external sphincter did not differ after two techniques (Appendix Table F181). ^383^ The rates of self-reported fecal and flatus incontinence were the same after both interventions. ^382^ Only one RCT reported a significant reduction in fecal urgency at 6 and 12 months postpartum after end-to-end technique compared to overlapping repair. ^381^ We estimated that 250 per 1,000 treated women would not experience fecal urgency at 6 months and 283 at 12 months postpartum.

#### Surrogate outcome - Subjective and objective measures of FI

Self-reported symptoms of FI and anal manometry were comparable after overlap or end-to-end anal sphincter repair (Appendix Tables F182 and F183). ^828^ FI scores and instrumental outcomes did not differ after two interventions (Appendix Table F184). ^383,^ ^384^

### Effects of Clinical Interventions to Prevent FI after Delivery

The effects of episiotomy were examined in two RCTs, ^386,^ ^387^ the effects of Cesarean or vaginal delivery were compared in two RCTs, ^388,^ ^389^ the effects of delayed or immediate pushing in the second stage of labor with epidural analgesia in one RCT, ^390^ and the effects of delivery by forceps or vacuum extractor in three RCTs ^391^ – ^393^ (Appendix Table F151).

#### Patient outcome - FI

Self-reported FI 18 months postpartum was the same after restrictive or liberal episiotomy. ^386^ The same proportion of women after mediolateral episiotomy or vaginal birth experienced FI (Appendix Table F185). ^387^

Cesarean vs. vaginal delivery resulted in the same rates of fecal and flatus incontinence at 3 months and 2 years postpartum. ^388,^ ^389^ However, only 43 percent of women randomized to vaginal delivery underwent Cesarean section.

Delayed or immediate pushing in the second stage of labor with epidural analgesia demonstrated the same rates of FI and sphincter defects in ultrasound at 3 months postpartum. ^390^

Delivery with a vacuum extractor tended to increase the risk of anal (RR 3.5, 95 percent CI 1.0; 12.2) ^393^ or FI (RR 1.8) ^391^ compared to forceps delivery with borderline significance of the differences (Appendix Table F185).

#### Surrogate outcome - Subjective and objective measures of FI

Self-reported FI scores and instrumental outcomes did not differ after all tested treatments.(Appendix Table F186)

#### Summary

No evidence suggested that Cesarean section or instrumental delivery can prevent FI postpartum compared to vaginal delivery.

### Effects of Early Ultrasound Diagnosis of Anal Obstetric Trauma

Clinical and ultrasound examination of the anal sphincter to diagnose tears followed by immediate surgical repair were examined in one well-designed RCT of 752 nulliparous women with second-degree perineal tear (Appendix Table F187). ^385^

#### Patient outcomes - FI

Self-reported FI and fecal urgency at 3 months and 1 year of followup did not differ among women who underwent ultrasound examinations compared to clinical examinations alone. Severe FI was reduced by 60 percent after ultrasound examination at 3 months (RR 0.4, 95 percent CI 0.2; 0.7) with no differences at 1 year of followup.

In conclusion, effective clinical interventions to reduce the risk of FI related to obstetric trauma are not well known and require future investigation.

### Effects of Surgical Interventions on FI in Females with Rectal Prolapse

The effects of surgical procedures on FI in women with full-thickness rectal prolapse were evaluated in two small and underpowered RCTs. ^413,^ ^414^ Abdominal resection rectopexy was compared to perineal rectosigmoidectomy and pelvic floor repair in 20 elderly female patients with FI who were followed up for 17 months. ^413^

#### Patient outcome - Continence

Both treatments resulted in continence rate of 40 percent (Appendix Table F188). Marlex mesh posterior rectopexy alone cured 56 percent and sigmoidectomy combined with a sutured posterior rectopexy cured 46 percent of 29 women with full-thickness rectal prolapse with no significant differences between treatments. ^414^

### Effects of Surgical Interventions on Females with FI

The effects of surgical interventions on neuropathic FI in community dwelling women were examined in several RCTs. ^428,^ ^829^ – ^831^

#### Patient outcome - Continence

Gluteus maximus transposition failed to cure 33 percent and total pelvic floor postanal repair with anterior levatoroplasty failed to cure 42 percent of women with post obstetric FI (Appendix Table F189). ^428^ Total pelvic floor repair cured 75 percent, postanal repair cured 33 percent, and anterior levatoroplasty and sphincter plication cured 33 percent of 36 women 28–75 years with neuropathic FI with no statistically significant differences between groups. ^829^ Adjuvant biofeedback following anal sphincter repair and anterior overlapping sphincter repair cured <6 percent of 38 females with persistent FI and external anal sphincter defect with no statistically significant differences between groups. ^830^

#### Surrogate outcome - Subjective and objective measures of severity of FI

Self-reported FI scores, patient satisfaction, and quality of life were comparable after the tested interventions (Appendix Table F190). ^385,^ ^428^ Surgeries resulted in random differences in instrumental outcomes inconsistent in the direction and effect size (Appendix Table F191). Small changes in maximum resting pressure were observed after adjuvant internal anal sphincter plication in pelvic floor repair compared to pelvic floor repair alone in 33 women with severe neuropathic FI related to vaginal delivery. ^831^

#### Patient outcome - FI

FI did not differ at 12 months after total abdominal or subtotal abdominal hysterectomy in a well-designed RCT of 279 women with benign uterine diseases. ^754^

#### Summary

Overall, limited evidence from small RCTs suggested that surgical procedures result in comparable risk of FI and quality of life. The effect size varied depending on the definition of FI and baseline cause and severity of FI. The effectiveness of the interventions in the subgroups of different age and severity categories require future investigation.

### Effects of Clinical Interventions in Men with Prostate Diseases on the Risk of FI

#### Patient outcomes

##### Continence

The effects of radiotherapy on FI in men with prostate diseases were examined in three RCTs (Appendix Table F151). ^780,^ ^788,^ ^790^ Both regimes of radiation resulted in more than an 80 percent continence rate. ^780^

##### FI

Three-dimensional conformal radiotherapy with a dose of 68Gy reduced rates of FI with frequent pad use in 7 percent compared to 12 percent after a dose of radiation of 78Gy at 4 years (RR 0.5, 95 percent CI 0.3; 0.9) but not at 5 years of followup (Appendix Table F192). ^788^ Patients with prostate cancer reported the same use of sanitary shields for stool leakage after radiotherapy or active surveillance. ^790^

#### Surrogate outcome - Subjective measure of severity of FI

Self-reported stool leakage tended to be greater after radiotherapy compared to active surveillance (Appendix Table F193). ^790^

### Effects of Bowel Management on FI in Patients with Spinal Cord Injury

#### Surrogate outcomes - Subjective measures of severity of FI

Transanal irrigation showed a small positive effect compared to conservative bowel management in 87 patients after spinal cord injury and symptoms of neurogenic bowel dysfunction (Appendix Table F194). ^832^ Neurogenic bowel dysfunction scores were reduced by 3 percent, St Mark's FI scores by 7 percent, and Cleveland Clinic constipation scores by 6 percent. The other incontinence outcomes, including the American Society of Colon and Rectal Surgeons FI scores, influence of FI on daily activities, and the number of episodes of clothes change, however, showed no differences (Appendix Table F194).

### Effects of Different Techniques of Hemorrhoidectomy on FI

The effects of hemorrhoidectomy on FI in adults were examined in nine RCTs (Appendix Table F151). ^394^ – ^402^

#### Patient outcomes

##### Continence

Several interventions resulted in fecal continence in all patients, including stapled and excision hemorrhoidectomy, ^394^ ligature and open diathermy hemorrhoidectomy, ^396^ submucosal hemorrhoidectomy with radiofrequency bistouries and Conventional Parks' hemorrhoidectomy, ^399^ excisional hemorrhoidectomy with ultrasonically activated scalpel, and closed excisional hemorrhoidectomy assisted by electrocautery ^401^ (Appendix Table F195). The rates of continence were not consistent across RCTs; for example, all patients were continent after ligature haemorrhoidectomy in one, ^396^ but only 67 percent in another trial. ^398^ The rates of FI after open haemorrhoidectomy varied from 0.1 percent in a small RCT (N=42) ^397^ to 7 percent in an RCT with 250 patients. ^400^

##### Improvement in FI

Improvement in FI did not differ after open or closed hemorrhoidectomy. ^400^ However, no statistical differences in outcomes after the tested procedures were shown. Self-reported increase in FI was observed in 15 percent of patients after ligature and in 25 percent of patients after open diathermy haemorrhoidectomy (RR not significant) (Appendix Table F196). ^396^

#### Surrogate outcome - Objective measure of severity of FI

Anorectal outcomes demonstrated inconsistent changes across four RCTs, ^397,^ ^400^ – ^402^ with significant differences in one. ^397^ (Appendix Table F197).

### Effects of Clinical Interventions in Patients with Colorectal Diseases on FI (FI-Secondary Outcome)

The effects of surgical interventions on FI were compared in patients with anorectal abscesses, ^415^ fistula-in-ano, ^416^ – ^418^ anal fissure, ^419^ – ^423^ and adenocarcinoma of the rectum ^424^ – ^426^ (Appendix Table F151).

#### Patient outcome - FI

Incision, drainage, and fistulectomy with primary partial internal sphincterectomy compared to incision and drainage alone did not reduce the risk of flatus incontinence and soiling in patients with anorectal abscesses (Appendix Table F198). ^415^ Special fibrin sealant combined with intra-adhesive cefoxitin, surgical closure of primary opening, or both modifications resulted in fecal continence in all patients with chronic anal fistula. ^416^ Adjuvant radiotherapy before total excision in patients with rectal cancer consistently increased the risk of FI in three RCTs, by 60 percent during the day (RR 1.6, 95 percent CI 1.4; 1.9), by 90 percent during the night (RR 1.9, 95 percent CI 1.4; 2.6), by 70 percent in utilization of pads (RR 1.7, 95 percent CI 1.4; 2.1) compared to mesorectal excision, ^424^ and by 220 percent (RR 2.2, 95 percent CI 1.2; 4.2) compared to the low anterior resection. ^424^ The harm of adjuvant radiotherapy reported in an RCT of 171 patients who survived for a minimum of 5 years after treatment with an increased relative risk of incontinence of liquid stool (RR 2.1, 95 percent CI 1.3; 3.2), incontinence of solid stool (RR 4.1, 95 percent CI 1.2; 14.2), and utilization of pads (RR 2.2, 95 percent CI 1.4; 3.5) ^425^ was larger. We estimated that surgery without adjuvant radiation would avoid 240 cases of daytime FI per 1,000 treated, ^424^ 310 cases of self-reported FI, ^424^ 260 cases of loose stool, and 110 cases of loose solids. ^425^ Adjuvant radiation also restricted social activities almost three time more often compared to surgery (RR 2.9, 95 percent CI 1.4; 5.8). ^425^

#### Surrogate outcome - Subjective measures of severity of FI

Postoperative radiotherapy, in addition to intensive daily pelvic floor muscle training with intra-anal biofeedback, improved the modified Cleveland Incontinence Scores at 1 year by 5.6 percent (mean difference -0.6, 95 percent CI -1.0; -0.2) compared to behavioral treatments without radiation (Appendix Table F199). ^426^

The clinical effects of glyceril trinitrate application were compared to lateral sphincterotomy with no significant difference in FI among patients with chronic anal fissure. ^419^ – ^423^ Quality of life was the same after both treatments. ^422^

The trial that compared dermal island flap anoplasty with cutaneous advancement flap into the rectum to conventional open fistulotomy or seton insertion in 20 patients with fistula-in-ano reported comparable FI scores (Appendix Table F199). ^418^ Another RCT did not show difference in FI Wexner scores after internal sphincterotomy compared to the application of 0.25 percent nitroglycerin tid to perianal area in 90 patients with symptomatic chronic anal fissures (Appendix Table F199). ^422^

A trial that compared dermal island flap anoplasty with cutaneous advancement flap into the rectum with conventional open fistulotomy or section in 20 patients with fistula-in-ano reported comparable FI scores. ^418^ Another RCT did not show differences in FI. Wexner scores after internal sphincterotomy compared the application of 0.25 percent nitroglycerin tid to the perineal area in 90 patients with symptomatic chronic anal fissures ^422^ (Appendix Table F199).

### Effects of Clinical Interventions in Patients with Rectal Prolapse on FI

The effects of clinical interventions in patients with rectal prolapse on FI were examined in seven RCTs (Appendix Table F151). ^406^ – ^412^

#### Patient outcome - FI

The risk of complete FI was reduced by 60 percent (RR 0.4, 95 percent CI 0.2; 0.7) after posterior sutured abdominal rectopexy combined with sigmoidectomy and end-to-end stapled anastomosis compared to polyglycolic acid mesh rectopexy without sigmoidectomy (Appendix Table F200). ^406^

#### Surrogate outcome - Subjective and objective measures of severity of FI

Surgical procedures did not reduce the risk of FI, self-reported severity scores, or instrumental outcomes (Appendix Table F201).

### Effects of Surgical Treatments of Anal Sphincter on FI

The effects of surgical treatments of anal sphincter on FI related to chronic anal fissure, fistulas, or neurogenic causes were examined in several RCTs (Appendix Table F151). ^427,^ ^833^ – ^839^

#### Patient outcomes

##### Continence

Open lateral internal sphincterotomy, as well as the anal administration of isosorbide dinitrate, resulted in fecal continence in all 63 patients with chronic anal fissure (Appendix Table F202). ^834^

##### FI

Implantation of artificial bowel sphincter reduced urge FI by 80 percent (RR 0.2, 95 percent CI 0.2; 0.3), pad utilization by 40 percent (RR 0.6, 95 percent CI 0.5; 0.7), and restrictions in physical activities by 60 percent (RR 0.4, 95 percent CI 0.3; 0.5) compared to baseline levels (Table 68 and Appendix Table F202). ^427^

Table 68 Comparative effectiveness of surgical interventions in anal sphincter on FI in adults (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment/ Number Treated | Number of Cases After Control Treatment/ Number Treated | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Wiley, 2004 ^833^ | Closed lateral internal sphincterotomy (Hoffman and Goligher) using a short stab incision and blind division of internal sphincter guided by the surgeon finger | Open lateral sphincterotomy (Parks) via a 1cm radial incision with division of internal sphincter under direct vision | Self-reported deterioration in FI | 2/38 | 10/41 | 5.3 | 24.4 | 0.2 | 5 | 191
N = 79 | | | | | | | | (0.1; 0.9) | (4; 53) | (19; 232)A
54% female
12 month followup
Wong, 2002 ^427^ | Implantation of Acticon trade mark artificial bowel sphincter - solid silicone elastomer device | Baseline condition | Using pad for FI | 60/112 | 99/112 | 54.0 | 88.0 | 0.6 | 3 | 340
N = 112 | | | | | | | | (0.5; 0.7) | (2; 4) | (238; 437)A
75% female | | | Using diapers for FI | 19/112 | 57/112 | 17.0 | 51.0 | 0.3 | 3 | 340
12 month followup | | | | | | | | (0.2; 0.5) | (2; 4) | (244; 401)A
| | | Avoiding physical activities due to FI | 32/112 | 91/112 | 29.0 | 81.0 | 0.4 | 2 | 520
| | | | | | | | (0.3; 0.5) | (2; 2) | (423; 600)A
Osterberg, 2004 ^837^ | Anterior levatorplasty with mobilization of external sphincter | Anal (and vaginal in women) plug electrostimulation of the pelvic floor with stimulation frequency was 25 Hz and the duration 1.5 seconds, with a pulse-train interval of 3 seconds | Self-reported improvement in FI at 3 months | 28/35 | 19/35 | 80.0 | 54.3 | 1.5 | 4 | 257
N = 70 | | | | | | | | (1.0; 2.1) | (2; 43) | (23; 588)E
79% female | | | Self-reported improvement in FI at 24 months | 26/35 | 19/35 | 74.3 | 54.3 | 1.4
12 month followup | | | | | | | | (1.0; 2.0)
| | | Use of pads for FI at 1 year | 10/35 | 15/35 | 28.6 | 42.9 | 0.7
| | | | | | | | (0.3; 1.3)
| | | Physical handicap due to FI at 1 year | 9/35 | 19/35 | 25.7 | 54.3 | 0.5 | 4 | 286
| | | | | | | | (0.2; 0.9) | (2; 18) | (55; 407)A

Bold - significant difference in outcomes at 95% confidence level;

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

Progression of FI was reduced by 80 percent (RR 0.2, 95 percent CI 0.1; 0.9) after closed compared to open lateral sphincterotomy. ^833^ Improvement in FI was increased by 40–50 percent after anterior levatorplasty with mobilization of external sphincter compared to anal (and vaginal in women) plug electrostimulation of the pelvic floor ^837^ in patients with idiopathic severe refractory FI. Physical restrictions were reduced by 50 percent (RR 0.5, 95 percent CI 0.2;0.9).

#### Surrogate outcome - Subjective and objective measures of severity of FI

Artificial bowel sphincter reduced FI scores (0–120 for complete FI) from 106 to 48 (mean difference -1.7, 95 percent CI -1.4;-2.0) or by 2 percent compared to the baseline condition. ^427^ Artificial bowel sphincters reduced the Cleveland Clinic Scoring and the American Medical Systems quality of life questionnaire specific to FI compared to usual supportive care. ^839^ (Appendix Table F203).

Guidance by endoanal ultrasound of injections of silicon biomaterial into inter-sphincteric space and internal anal sphincter improved the Wexner and visual analog scores and FI Quality of Life Index compared to injections without a guide (Appendix Table F204). ^838^

All procedures resulted in small inconsistent changes in anal manometry outcomes (Appendix Table F204).

#### Surrogate outcome - Dynamic graciloplasty

One multicenter noncontrolled nonramdomized clinical trial (Dynamic Graciloplasty Therapy Study Group) reported significant improvements quality of life (Medical Outcomes Study Short Form 36 physical function and social functioning). The majority of nonstoma patients (56 to 62 percent) at 12–24 months had continent stools/total number of stools ≥50 percent. In the stoma patients 37.5 percent at 12 months to 43 percent at 24 months reported having continent stools. ^429,^ ^430^

#### Summary

In conclusion, implanting an artificial bowel sphincter demonstrated some consistent effects to reduce the risk of FI. Adjuvant radiation in patients with prostate cancer resulted in a consistent significant increase in FI compared to surgery alone. The protective effects on FI of surgeries for hemorrhoids, rectal prolapse, rectal cancer, and anal fissures are not replicable across RCTs and require future confirmation in well-designed long-term RCTs.

### Surgical Interventions (Restorative Proctocolectomy) on FI in Adults (FI as Secondary Outcome)

Surgical interventions (restorative proctocolectomy) on FI in adults (FI as secondary outcome) were examined in patients with cancer in 13 RCTs, ^840^ – ^852^ in patients with ulcerative colitis in four RCTs, ^431^ – ^434^ and one retrospective cohort, ^853^ in patients with rectal prolapse in one RCT, ^854^ and in patients with sphincter damage in one RCT ^855^ (Appendix Table F151).

#### Patient outcome - Continence

The majority of patients with cancer were continent after standardized resection with J pouch anastomosis or straight coloanal anastomosis across RCTs (Table 69). Rates of FI did not differ between treatment groups. Abdominal colectomy with hand sewing or double stapling the pouch to the anal canal provided the highest rates of continence in patients with ulcerative colitis with no differences between the two surgeries. ^431^ All patients were continent after duplicated or quadruplicated ileal reservoirs in restorative proctocolectomy with no differences between them. ^432,^ ^433^ Abdominal rectopexy with or without sigmoidectomy resulted in the same continence rates in patients with rectal prolapse. ^854^

Table 69 Surgical interventions (diversion) on FI in adults (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment/ Number Treated | Number of Cases After Control Treatment/ Number Treated | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Patients with Cancer
Seow-Choen, 1995 ^840^ | Ultra-low anterior resection with total mesorectal excision and 8cm J colonic pouch-anal anastomosis (median distance of anastomosis from the anal verge 3cm) | Ultra-low anterior resection with total mesorectal excision and straight coloanal anastomosis (median distance of anastomosis from the anal verge 3.25cm) | Fecal continence | 19/20 | 14/20 | 95.0 | 70.0 | 1.4 | 4 | 250
N = 40 | | | | | | | | (1.0; 1.8) | (2; 1,046) | (1; 588)E
35% female
12 month followup
Ho, 2001 ^841^ | Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Standardized ultra-low anterior resection with straight coloanal anastomosis, the descending colon was connected to the anorectal stump | FI | 0/16 | 1/19 | 0 | 5.0 | 0.4
N = 42 | | | | | | | | (0.0; 9.0)
60% female | | | Incontinence to gas | 0/16 | 3/19 | 0 | 16.0 | 0.2
24 month followup | | | | | | | | (0.01; 3.0)
Ho, 2002 ^842^ | Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Standardized ultra-low anterior resection with straight coloanal anastomosis, the descending colon was connected to the anorectal stump | Self-reported fecal continence | 6/6 | 6/6 | 100.0 | 100.0
N = 12
17% female
12 month followup
Soliani, 1992 ^843^ | Conceal Colostomy Plug fit with a two-piece Conceal system | Conceal Colostomy Plug fit with a one-piece Conceal system | Improved fecal continence | 5/36 | 7/57 | 13.9 | 12.3 | 1.1
N = 57 | | | | | | | | (0.4; 3.3)
32% female
.5 months followup
Hallbook, 1996 ^844^ | Low anterior resection with total mesorectal excision with straight anastomosis 6 to 8cm in length | Low anterior resection with total mesorectal excision colonic J pouch anastomosis 6 to 8cm in length | Symptomatic anastomotic fecal leakage | 8/52 | 1/45 | 15.0 | 2.0 | 6.9
N = 100 | | | | | | | | (0.9; 53.3)
45% female | | | Proportion with frequent nocturnal bowel movements | 12/52 | 3/45 | 24.0 | 7.0 | 3.5 | 6 | 170
12 month followup | | | | | | | | (1.0; 11.5) | (1; 340) | (3; 735)E
| | | Ability to always defer defecation >30 minutes (%) | 8/52 | 22/45 | 15.0 | 49.0 | 0.3 | 3 | 340
| | | | | | | | (0.2; 0.6) | (2; 6) | (178; 414)A
| | | Ability to always evacuate the bowel <15 minutes (%) | 29/52 | 15/45 | 55.0 | 34.0 | 1.7 | 5 | 210
| | | | | | | | (1.0; 2.7) | (2; 81) | (12; 578)E
| | | Never a sensation of incomplete evacuation (%) | 5/52 | 10/45 | 9.0 | 22.0 | 0.4
| | | | | | | | (0.2; 1.2)
| | | Bowel function does not affect well-being at all | 14/52 | 29/45 | 26.0 | 65.0 | 0.4 | 3 | 390
| | | | | | | | (0.3; 0.7) | (2; 5) | (203; 485)A
Seow-Choen, 1995 ^840^ | Ultra-low anterior resection with total mesorectal excision and 8cm J colonic pouch-anal anastomosis (median distance of anastomosis from the anal verge 3cm) | Ultra-low anterior resection with total mesorectal excision and straight coloanal anastomosis (median distance of anastomosis from the anal verge 3.25cm) | Bowel urgency < 15 minutes | 2/20 | 4/20 | 10.0 | 20.0 | 0.5
N = 40 | | | | | | | | (0.1; 2.4)
35% female | | | Bowel urgency > 15 minutes | 17/20 | 16/20 | 85.0 | 80.0 | 1.1
12 month followup | | | | | | | | (0.8; 1.4)
| | | Nocturnal fecal leakage | 1/20 | 5/20 | 5.0 | 25.0 | 0.2
| | | | | | | | (0.0; 1.6)
| | | Use of pads for FI | 1/20 | 3/20 | 5.0 | 15.0 | 0.3
| | | | | | | | (0.0; 2.9)
Ho, 2001 ^841^ | Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6 cm in length | Standardized ultra-low anterior resection with straight coloanal anastomosis. Descending colon was anastomosed to the anorectal stump | FI - need to wear pad | 0/16 | 3/19 | 0 | 16.0 | 0.2
N = 42 | | | | | | | | (0.0; 3.0)
60% female | | | FI with alterations in life style | 4/16 | 5/19 | 25.0 | 26.3 | 1.0
24 month followup | | | | | | | | (0.3; 3.0)
| | | Nocturnal fecal leakage | 0/16 | 1/19 | 0 | 5.0 | 0.4
| | | | | | | | (0.0; 9.0)
Ho, 2002 ^842^ | Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Standardized ultra-low anterior resection with straight coloanal anastomosis, the descending colon was anastomosed to the anorectal stump | Rectosphincteric inhibitory reflex present, % | 2/6 | 3/6 | 33.3 | 50.0 | 0.7
N = 12 | | | | | | | | (0.2; 2.7)
17% female | | | Presence of technetium TC 99m tin-colloid liquid in descending colon 56 hours after the test | 3/6 | 2/6 | 50.0 | 33.3 | 1.5
12 month followup | | | | | | | | (0.4; 6.0)
Ho, 2005 ^845^ | Standardized total mesorectal excision with at least 2cm of distal tumor clearance. J-pouch was constructed from descending colon 6cm in length using an Autosuture ILA 75 linear cutting stapler | Standardized total mesorectal excision with at least 2cm of distal tumor clearance. Coloplasty pouch was anastomosed to stapled anorectal stump | Nocturnal fecal leak | 7/44 | 4/44 | 15.6 | 8.3 | 1.8
N = 88 | | | | | | | | (0.6; 5.6)
40% female | | | Soiling at passing flatus | 8/44 | 5/44 | 18.8 | 11.1 | 1.6
12 month followup | | | | | | | | (0.6; 4.5)
| | | Toilet dependency | 4/44 | 6/44 | 9.4 | 13.9 | 0.7
| | | | | | | | (0.2; 2.2)
| | | Incomplete evacuation | 21/44 | 17/44 | 46.9 | 38.9 | 1.2
| | | | | | | | (0.8; 2.0)
| | | Internal anal sphincter fragmentation | 3/44 | 4/44 | 6.3 | 8.3 | 0.8
| | | | | | | | (0.2; 3.2)
Machado, 2005 ^846^ | Low anterior resection and total mesorectal excision with a colonic J-pouch anastomosis | Low anterior resection and total mesorectal excision with a colonic J-pouch or a side-to-end anastomosis. | Defer defections for >30 minutes | 25/36 | 16/35 | 69.0 | 46.0 | 1.5
N = 71 | | | | | | | | (1.0; 2.3)
22% female | | | Sensation of incomplete evacuation | 8/36 | 11/35 | 21.0 | 31.0 | 0.7
24 month followup | | | | | | | | (0.3; 1.5)
| | | Regular use of pad for FI | 12/36 | 14/35 | 33.0 | 40.0 | 0.8
| | | | | | | | (0.5; 1.5)
Laurent, 2005 ^847^ | Total mesorectal excision and hand sewn colonic J-pouch-anal anastomosis (6cm) | Total mesorectal excision and stapled colonic J-pouch-anal anastomosis (6cm) using PI-30 stapling instrument | Fecal urgency | 1/16 | 3/20 | 6.0 | 15.0 | 0.4
N = 37 | | | | | | | | (0.0; 3.6)
19% female | | | No pad requirement for FI | 16/16 | 17/20 | 100.0 | 85.0 | 1.2
24 month followup | | | | | | | | (0.9; 1.4)
Lazorthes, 1997 ^848^ | Complete rectal excision with coloanal anastomosis 6cm J-pouch group | Complete rectal excision with coloanal anastomosis 10cm J-pouch group | Bowel urgency | 1/23 | 2/24 | 4.3 | 8.3 | 0.5
N = 47 | | | | | | | | (0.1; 5.4)
60% female
24 month followup
Jiang, 2005 ^849^ | Side-to-end anastomosis after low anterior resection | Colonic J-pouch reconstruction after low anterior resection | Urgency | 1/24 | 1/24 | 4.2 | 4.2 | 1.0
N=48\44% female | | | | | | | | (0.1; 15.1)
24 month followup | | | Fecal leakage | 2/24 | 2/24 | 8.3 | 8.3 | 1.0
| | | | | | | | (0.2; 6.5)
| | | Use of pad for FI | 1/24 | 2/24 | 4.2 | 8.3 | 0.5
| | | | | | | | (0; 5.2)
Patients with Ulcerative Colitis
Reilly, 1997 ^431^ | Abdominal colectomy excising anal transition zone and hand sewing the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Abdominal colectomy preserving anal transition zone and double stapling the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Complete fecal continence during days | 12/15 | 14/17 | 77.0 | 84.0 | 1.0
N = 41 | | | | | | | | (0.7; 1.4)
34% female
6 month followup
Johnston, 1996 ^432^ | Duplicated (J) pelvic ileal reservoirs in restorative proctocolectomy constructed with 30–40cm of ileum | Quadruplicated (W) reservoir pelvic ileal reservoirs in restorative proctocolectomy, constructed with 30–40cm of ileum | Bowel frequency at night | 4/31 | 5/29 | 12.9 | 17.2 | 0.7
N = 60 | | | | | | | | (0.2; 2.5)
57% female | | | Leakage of mucus (no patients reported fecal loss or pad use) | 4/31 | 4/29 | 12.9 | 13.8 | 0.9
12 month followup | | | | | | | | (0.3; 3.4)
| | | Ability to defer defecation >30 minutes | 27/31 | 25/29 | 87.1 | 86.2 | 1.0
| | | | | | | | (0.8; 1.2)
| | | Ability to defer defecation >15 minutes | 28/31 | 29/29 | 90.3 | 100.0 | 0.9
| | | | | | | | (0.8; 1.0)
Selvaggi, 2000 ^433^ | Ileal pouch-anal anastomosis including total colectomy, total rectal excision, and two-limb J reservoir | Ileal pouch-anal anastomosis including total colectomy, total rectal excision, and four-limb W reservoir | Number with scores <11 in fecal continence scale from 0-continence to 24 - complete incontinence | 10/11 | 12/13 | 90.9 | 92.3 | 1.0
N = 24 | | | | | | | | (0.8; 1.3)
58% female | | | Absence of rectoanal inhibitory reflex | 1/11 | 1/13 | 9.1 | 7.7 | 1.2
12 month followup | | | | | | | | (0.1; 16.8)
Reilly, 1997 ^431^ | Abdominal colectomy excising anal transition zone and hand sewing the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Abdominal colectomy preserving anal transition zone and double stapling the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Complete fecal continence during nights | 5/15 | 11/17 | 36.0 | 62.0 | 0.5
N = 41 | | | | | | | | (0.2; 1.1)
34% female | | | Wearing a pad for FI | 1/15 | 4/17 | 7.0 | 26.0 | 0.3
6 month followup | | | | | | | | (0.0; 2.3)
Patients with Rectal Prolapse
McKee, 1992 ^854^ | Abdominal rectopexy without sigmoidectomy | Abdominal rectopexy with sigmoidectomy of redundant sigmoid colon and end-to-end anastomosis of colon and rectum made in pelvic brim | FI using saline solution infusion test | 1/9 | 3/9 | 11.1 | 33.3 | 0.3
N = 18 | | | | | | | | (0.0; 2.6)
50% female
20 month followup

Bold - significant difference in outcomes at 95% confidence level;

E - number of excessive events per 1,000 treated; A - number of avoided events per 1,000 treated;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence)

Fecal continence was reported in 75 percent of 1,885 patients operated for chronic ulcerative colitis at 1 year and gradually decreased to 59 percent after 20 years of followup (Appendix Table F205). ^853^ The proportion of patients continent after surgery increased during the last decades from 57 percent in 1981-1985 to 70 percent from 1996-2000 (Appendix Table F206). ^853^

#### Surrogate outcome - Subjective and objective measures of severity of FI

Severity of FI differed between types of surgical anastomosis in patients with cancer (Appendix Table F207). Low anterior resection with straight anastomosis increased FI scores by 61 percent compared to J pouch anastomosis (mean difference in a scale from 0 to18 for complete FI, 1.2, 95 percent CI 0.8; 1.7). ^844^ In contrast, another RCT showed a significant increase in the Wexner FI scores after J anastomosis (mean difference 1.3, 95 percent CI 0.5; 2.0), ^841^ The Fecal Incontinence Severity Index decreased after J anastomosis (mean difference -4.6, 95 percent CI -5.6; -3.5) and the FI quality of life scale improved (mean difference 0.7, 95 percent CI 0.1; 1.3). ^856^ Severity of FI did not differ after the tested interventions in patients with ulcerative colitis or rectal prolapse.

Anal manometry outcomes demonstrated random changes after surgical interventions with inconsistent direction and effect size. Smaller RCTs reported greater differences (Appendix Table F208).

#### Summary

In conclusion, different types of anastomosis (J-pouch-anal or straight) combined with resection of cancer resulted in comparable fecal continence rates across the RCTs. Surgical interventions in patients with ulcerative colitis were comparable between active treatments for fecal continence in the majority of the patients during the first 10 years after surgery with an increased risk of FI during longer period of followup. The effects of treatments on quality of life were inconsistent in direction and effect size.

Clinical interventions resulted in comparable incidence and progression of FI in the majority of the RCTs. Significant relative benefits on fecal continence were reported in small trials of <100 subjects (Table 70). Definite harm of adjuvant radiotherapy compared to surgery alone was shown in RCTs of 597 patients ^424^ and 171 patients ^425^ with rectal cancer. Short-term benefits of pelvic floor muscle training supplemented with bladder training and supervised by nurses was reported in RCTs of 747 pregnant women. ^251^ Early detection of anal sphincter tears after vaginal delivery, followed by immediate surgical repair, significantly reduced the risk of FI 3 months and 1 year postpartum in RCTs of 752 pregnant women. ^385^ The significant results of small RCTs need future confirmation in well-designed long-term trials.

Table 70 Comparative effectiveness of clinical interventions on FI in community dwelling adults (significant differences only shown)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment/ Number Treated | Number of Cases After Control Treatment/ Number Treated | Relative Risk | Number Needed to Treat | Number of Attributable Events/1,000 Treated
Sample | | | | | | (95% CI) | (95% CI) | (95% CI)
Followup
Fecal Continence
Fynes, 1999 ^372^ | Augmented biofeedback training of pelvic floor with audiovisual feedback and electric stimulation of slow and fast twitch fibers for 12 weeks | Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor exercise for 12 weeks | Cured (became asymptomatic) | 15/20 | 7/19 | 2.04 | 3 | 382
N = 40 | | | | | | (1.07; 3.86) | (1; 37) | (27; 1,055)E
100% female
3 month followup
Seow-Choen, 1995 ^840^ | Ultra-low anterior resection with total mesorectal excision and 8cm J colonic pouch-anal anastomosis (median distance of anastomosis from the anal verge 3cm) | Ultra-low anterior resection with total mesorectal excision and straight coloanal anastomosis (median distance of anastomosis from the anal verge 3.25cm) | Fecal continence | 19/20 | 14/20 | 1.36 | 4 | 250
N = 40 | | | | | | (1.00; 1.84) | (2; 1,046) | (1; 588)E
35% female
12 month followup
Peeters, 2005 ^424^ | Radiotherapy with total dose of 25Gy administered in 5 fractions over 5 to 7 days before total mesorectal excision | Total mesorectal excision | Complete fecal continent (fecal incontinent at baseline) | 116/306 | 180/291 | 0.61 | 4 | 240
N = 597 | | | | | | (0.52; 0.73) | (3; 6) | (299; 170)A
38% female | | | Always fecal incontinent | 43/306 | 15/291 | 2.73 | 11 | 90
60 month followup | | | | | | (1.55; 4.80) | (5; 36) | (27; 190)E
Fernando, 2006 ^381^ | Primary overlap. 1st row of sutures inserted ~1.5cm from one side of torn edge of external anal sphincter and carried through to within 0.5cm of other edge. 2nd row of sutures inserted to attach loose end of overlapped muscle | End-to-end repair of the external anal sphincter | Fecal continence | 32/32 | 24/32 | 1.33 | 4 | 240
N = 64 | | | | | | (1.08; 1.63) | (2; 16) | (61; 478)E
100% female
12 month followup
Luukkonen, 1992 ^406^ | Posterior sutured abdominal rectopexy combined with sigmoidectomy complete rectal prolapse and end-to-end anastomosis made with a circular stapler | Polyglycolic acid mesh rectopexy without sigmoidectomy for complete rectal prolapse anterior rectal wall free | Complete anal continence | 9/33 | 11/15 | 0.37 | 2 | 461
N = 30 | | | | | | (0.20; 0.70) | (2; 5) | (589; 219)A
33% female
22 month followup
Improvement in Fecal Continence
Leroi, 2005 ^377^ | Active sacral nerve continuous stimulation with pulse width of 210 microseconds, frequency 14 pulses/second, and amplitude adapted to the patient's perception of perineal and anal sphincter muscle contraction | Sham sacral nerve stimulation with lead turned off | Improvement in FI | 30/34 | 6/34 | 5.00 | 1 | 720
N = 34 | | | | | | (2.39; 10.44) | (1; 4) | (237; 1,605)E
91% female
1 month followup
Osterberg, 2004 ^837^ | Anterior levatorplasty with mobilization of external sphincter | Anal (and vaginal in women) plug electrostimulation of the pelvic floor with stimulation frequency was 25Hz and the duration 1.5 seconds, with a pulse-train interval of 3 seconds | Self-reported improvement in FI Improvement in Incontinence at 3 months | 28/35 | 19/35 | 1.47 | 4 | 257
N = 70 | | | | | | (1.04; 2.08) | (2; 43) | 23; 588)E
79% female
12 month followup
Davis, 2004 ^830^ | Anterior overlapping sphincter repair using interrupted nonabsorbable sutures and levatorplasty using absorbable sutures | Anterior overlapping sphincter repair plus visual or auditory biofeedback with dual-balloon pressure system during pelvic floor exercise 2 times/day | Symptomatic improvement in FI | 13/20 | 17/18 | 0.69 | 4 | 281
N = 38 | | | | | | (0.49; 0.97) | (2; 33) | (30;474)A
100% female
12 month followup
Tjandra, 2004 ^838^ | PTP injection into intersphincteric space and internal anal sphincter with guidance by endoanal ultrasound | PTP injection into intersphincteric space and internal anal sphincter without guidance by endoanal ultrasound | >50 percent improvement in Wexner's continence score | 29/12 | 16/11 | 1.73 | 3 | 290
N - 82 | | | | | | (1.12; 2.65) | (2; 20) | (49; 662)E
78% female
3 month followup
Dahlberg, 1998 ^425^ | Preoperative high-dose radiotherapy with 25Gy given in 5 fractions for 5–7 days followed by anterior resection of rectal cancer | Anterior resection of rectal cancer alone | Excellent operation with respect to bowel function | 12/84 | 28/87 | 0.44 | 6 | 180
N = 171 | | | | | | (0.24; 0.81) | (4; 17) | (60; 243 )A
51% female
60 month followup
Risk of FI
Glazener, 2001 ^251^ | Assessment by nurses of urinary incontinence with conservative advice on pelvic floor exercises supplemented with bladder training | Usual peripartum preparation | Any FI (to motions) | 12/371 | 25/376 | 0.49 | 16 | 61 (5; 79)A
N = 747 | | | | | | (0.25; 0.95) | (13; 206)
100% female
12 month followup
Dahlberg, 1998 ^425^ | Preoperative high-dose radiotherapy with 25Gy given in 5 fractions for 5–7 days followed by anterior resection of rectal cancer | Anterior resection of rectal cancer alone | Fecal urgency, toilet dependence | 25/84 | 5/87 | 5.18 | 4 | 240
N = 171 | | | | | | (2.08; 12.89) | (1; 15) | (65; 714)E
51% female | | | Bowel emptying difficulties | 44/84 | 31/87 | 1.47 | 6 | 160
60 month followup | | | | | | (1.04; 2.08) | (3; 74) | (14; 390)
| | | Incontinence of gas | 57/84 | 44/87 | 1.34 | 6 | 170
| | | | | | (1.04; 1.73) | (3; 49) | (20; 373)E
| | | Incontinence of loose stool | 42/84 | 21/87 | 2.07 | 4 | 260
| | | | | | (1.35; 3.18) | (2; 12) | (84; 524)E
| | | Incontinence of solid stool | 12/84 | 3/87 | 4.14 | 9 | 110
| | | | | | (1.21; 14.16) | (3; 157) | (6; 395)E
Peeters, 2005 ^424^ | Radiotherapy with total dose of 25Gy administered in 5 fractions over 5 to 7 days before total mesorectal excision | Total mesorectal excision | FI during day | 190/306 | 111/291 | 1.63 | 4 | 240
N = 597 | | | | | | (1.37; 1.93) | (3; 7) | (142; 354)E
38% female | | | FI during night | 98/306 | 49/291 | 1.90 | 7 | 150
60 month followup | | | | | | (1.40; 2.58) | (4; 15) | (69; 268)E
Peeters, 2005 ^424^ | Radiotherapy with total dose of 25Gy was administered with 5Gy fractions to rectum, perirectal tissues, anal sphincters, and regional lymph nodes before low anterior resection of rectal cancer | Low anterior resection of rectal cancer without preoperative radiotherapy | Self-reported FI | 12/21 | 11/43 | 2.23 | 3 | 310
N = 64 | | | | | | (1.19; 4.19) | (1; 20) | (49; 831)E
50% female | | | Self-reported gas incontinence | 15/21 | 20/43 | 1.54 | 4 | 250
60 month followup | | | | | | (1.01; 2.34) | (2; 226) | (4; 615)E
Fernando, 2006 ^381^ | Primary overlap. 1st row of sutures inserted ~1.5cm from one side of torn edge of external anal sphincter and carried through to within 0.5cm of other edge. 2nd row of sutures inserted to attach loose end of overlapped muscle. | End-to-end repair of the external anal sphincter | Fecal urgency | 1/32 | 10/32 | 0.10 | 4 | 283
N = 64 | | | | | | (0.01; 0.74) | (3; 12) | (316; 84)A
100% female | End-to-end technique to repair obstetric anal sphincter | Overlap technique to repair obstetric anal sphincter | Fecal urgency 12 months postpartum | 8/32 | 1/32 | 8.00 | 4 | 283
12 month followup | | | | | | (1.06; 60.32) | (0; 443) | (2; 2,195)E
| | | Fecal urgency 6 months postpartum | 9/32 | 2/32 | 4.50 | 4 | 250
| | | | | | (1.05; 19.22) | (1; 262) | (4; 1,293)E
Parellada, 2004 ^834^ | Surgical: open lateral internal sphincterotomy and mucose closure with chromic catgut. | Chemical: local 0.2% isosorbide dinitrate - pea-size quantity applied manually at the entrance of the anus, 3 times/day immediately after a warm bath, for 6 weeks. | Self-reported gas incontinence and fecal soiling | 9/30 | 0/33 | 20.84 | 3 | 299 E
N = 63 | | | | | | (1.26; 343.32)
96% female
24 month followup
Wong, 2002 ^427^ | Implantation of Acticon trade mark artificial bowel sphincter - solid silicone elastomer device | Baseline condition | Urge fecal incontinence | 22/112 | 100/112 | 0.22 | 1 | 690
N = 112 | | | | | | (0.15; 0.32) | (1; 2) | (604; 756)A
75% female
12 month followup
Johanson, 1999 ^391^ | Delivery with vacuum extractor | Forceps delivery | Self-reported FI, sometimes | 28/296 | 16/311 | 1.84 | 23 | 43
N = 607 | | | | | | (1.02; 3.33) | (8; 1,221) | (1; 120)E
100% female
60 month followup
Faltin, 2005 ^385^ | Clinical and ultrasound examination of the anal sphincter | Clinical examination alone | Self-reported severe fecal incontinence 3 months postpartum (Wexner scores >4) | 12/376 | 31/376 | 0.39 | 19 | 54
N = 752 | | | | | | (0.20; 0.74) | (14; 45) | (22; 69)A
100% female | | | Self-reported severe fecal incontinence 1 year postpartum (Wexner scores >4) | 11/376 | 23/376 | 0.48 | 29 | 35
12 month followup | | | | | | (0.24; 0.97) | (20; 454) | (2; 51)A
Lundby, 2005 ^857^ | Postoperative radiotherapy after anterior resection | Anterior resection alone | FI | 9/244 | 1/250 | 9.22 | 30 | 33
N = 494 | | | | | | (1.18; 72.24) | (4; 1,411) | (1; 285)E
50% female
15–20 year followup
Severity of FI
Osterberg, 2004 ^837^ | Anterior levatorplasty with mobilization of external sphincter | Anal (and vaginal in women) plug electrostimulation of the pelvic floor with stimulation frequency was 25Hz and the duration 1.5 seconds, with a pulse-train interval of 3 seconds | Physical handicap due to FI at 1 year | 9/35 | 19/35 | 0.47 | 4 | 286
N = 70 | | | | | | (0.25; 0.90) | (2; 18) | (55; 407)A
90% female
12 month followup
Dahlberg, 1998 ^425^ | Preoperative high-dose radiotherapy with 25Gy given in 5 fractions for 5–7 days followed by anterior resection of rectal cancer | Anterior resection of rectal cancer alone | Use of pad for FI | 41/84 | 19/87 | 2.23 | 4 | 270
N = 171 | | | | | | (1.42; 3.52) | (2; 11) | (92; 554)E
51% female | | | Restriction in social life because FI | 25/84 | 9/87 | 2.88 | 5 | 200
60 month followup | | | | | | (1.43; 5.80) | (2; 23) | (43; 480)E
Peeters, 2005 ^424^ | Radiotherapy with total dose of 25Gy administered in 5 fractions over 5 to 7 days before total mesorectal excision | Total mesorectal excision | Use of pads for fecal incontinence | 171/306 | 96/291 | 1.69 | 4 | 230
N = 597 | | | | | | (1.40; 2.05) | (3; 8) | (132; 347)E
38% female
60 month followup
Wiley, 2004 ^833^ | Closed lateral internal sphincterotomy (Hoffman and Goligher) using a short stab incision and blind division of the internal sphincter guided by surgeon's finger | Open lateral sphincterotomy (Parks) via a 1cm radial incision with division of the internal sphincter under direct vision | Self-reported deterioration in FI | 2/38 | 10/41 | 0.22 | 5 | 191
N = 79 | | | | | | (0.05; 0.92) | (4; 53) | (232; 19)A
54% female
12 month followup
Wong, 2002 ^427^ | Implantation of Acticon trade mark artificial bowel sphincter - solid silicone elastomer device | Baseline condition | Self reported using pad for FI | 60/112 | 99/112 | 0.61 | 3 | 340
N = 112 | | | | | | (0.50; 0.73) | (2; 4) | (238; 437)A
75% female | | | Self reported using diapers for FI | 19/112 | 57/112 | 0.33 | 3 | 340
12 month followup | | | | | | (0.21; 0.52) | (2; 4) | (244; 401)A
| | | Avoiding physician activities due to FI | 32/112 | 91/112 | 0.35 | 2 | 520
| | | | | | (0.26; 0.48) | (2; 2) | (423; 600)A
Peeters, 2006 ^788^ | Three-dimensional conformal radiotherapy 68Gy | Three-dimensional conformal radiotherapy 78Gy | FI as use of incontinence pads for rectal loss of blood, mucus, or stools (requiring use of pads more than twice a week) | 21/326 | 40/330 | 0.53 | 18 | 57
N = 669 | | | | | | (0.32; 0.88) | (12; 69) | (15; 83)A
0% female
12 month followup

Bold - significant differences at 95% confidence level;

number needed to treat to benefit one patient for positive patient outcomes (continence and improvement) or to harm one patient for negative patient outcomes (incontinence);

A - number of avoided events per 1,000 treated; E - number of excessive events per 1,000 treated

## Question 4. What are the Strategies to Improve the Identification of Persons at Risk and Patients who have UI and FI?

### Strategies to Improve the Identification of Persons at Risk and Patients who have UI

Evidence from large observational studies suggests that a substantial proportion of community dwelling adults have undiagnosed UI. Prevalence varied across gender and age groups. The majority (66.2 percent) of women with UI after pregnancy did not report the symptoms to their nurses or doctors. ^858^ Healthcare professionals did not assess bladder control in 77 percent and did not examine pelvic floor muscles during routine vaginal examination in 94 percent of pregnant women. ^859^ The majority of young women 18–23 years old (77 percent) with symptoms of UI never sought medical help, and only 11.5 percent received care they were satisfied with. ^860^ The prevalence of undiagnosed UI was consistent across Western countries: 55 percent for mid-age and older women from a large Australian Longitudinal Study on Women's Health, ^860^ 56 percent in an Austrian cohort, ^139^ 62 percent in the Netherlands, ^122^ and higher in Turkey (85 percent) ^861^ and in the United Arab Emirates (69.1 percent). ^862^ The prevalence of undiagnosed UI is higher in recent studies. For example, 75 percent of Swedish women with UI had not sought professional help, ^155^ 75 percent in Spain, 67 percent in France, 60 percent in Germany, ^112^ and 75 percent ^112^ to 86 percent ^478^ in the United Kingdom.

The prevalence of undiagnosed UI is also high in men; only one third of American men ^863^ and 46 percent of Swedish men ^583^ with UI received professional care for UI, and only 33 percent obtained information about UI from the health service. ^61^ Only 55 percent of men 45–75 years old with bothersome urinary symptoms contacted general practitioners, and only 40 percent of those were referred to a urologist for a specialized exam and advice. ^598^ Specialized care was given to 11 percent of adults with UI in Belgium. ^587^ Among males with overactive bladder symptoms living in 11 Asian countries, only 6 percent discussed this condition with a physician. ^864^

The proportion of older community dwelling adults with undiagnosed UI varied from 25 percent of men and 40 percent of women in Spain, ^35^ to 91 percent in Thailand, ^865^ and 82 percent in Japan. ^63^ Primary care providers in the United States assessed UI in 21 percent of older incontinent women and 10 percent of older incontinent men. ^521^ The prevalence of undiagnosed UI was highest in Black women and in Hispanic men. ^146^

The diagnostic pathway to detect persons at risk and patients with UI includes population-based epidemiologic surveys with validated questionnaires and scales, ^866^ clinical history, and simple self-administered diagnostic tests. Treatment decisions are made based on instrumental methods, including ultrasound and multi-channel urodynamics, considered as a “gold standard,” essential to decide the most effective intervention. ^867^

#### Valid questionnaires to assess UI (Appendix Table F209)

The Symptom and Quality of Life Committee of the International Consultation on Incontinence (ICI) systematically reviewed available questionnaires and scales to diagnose UI and evaluate quality of life in patients with UI. ^866^ The committee highly recommended the questionnaires with rigorous validity, reliability, and responsiveness in several clinical studies graded with the highest level of evidence (level A) (Appendix Table F210). ^866^ The ICI Questionnaire combined symptoms of UI and impact on life for both genders. ^868^ The Bristol Female Lower Urinary Tract Symptoms Questionnaire ^869^ and the Stress and Urge Incontinence and Quality of Life Questionnaire (SUIQQ) ^870^ are recommended to estimate the severity and impact on life of stress and urge UI in women (Appendix Table F211). ^866^ The ICS male questionnaire measures voiding patterns, stress, urge UI, and impact on quality of life related to UI. ^871^ The overactive bladder questionnaire demonstrated validity and reliability to measure symptoms of overactive bladder in males and females. ^872^ Most of the questionnaires are gender specific and include UI and other symptoms of lower urinary tract problems in females (Urogenital Distress Inventory; ^873^ Urogenital Distress Inventory-6; ^874^ Incontinence Severity Index; ^875^ Bristol Female Lower Urinary Tract Symptoms Questionnaire ^876^ and in males ICS Male, Lower Urinary Tract Symptoms ^877^ and Danish Prostatic Symptom Score, Lower Urinary Tract Symptoms ^878^ ). The questionnaires on Quality of Life in Persons with UI ^879^ and the Incontinence Classification System ^880^ estimate perceived UI, social interactions, personal strain, impact on sexual life, and overall health in both genders. Several scales are recognized as valid tools to measure quality of life in incontinent women: King's Health Questionnaire; ^881^ Incontinence Impact Questionnaire; ^882^ Incontinence Impact Questionnaire-7; UI Severity Score (UISS); ^883,^ ^884^ and CONTILIFE-Urinary Incontinence-Specific Measure of Quality of Life. ^885^ The committee did not find good evidence to recommend scales of quality of life in males. Standard recommendations developed by the Symptom and Quality of Life Committee of the ICI did not include sensitivity, specificity, and positive predictive likelihood of different questionnaires compared to objective physician diagnosis or instrumental methods. The assessment of validity based on significant correlation coefficients can be biased by the sample size of the studies and the distribution of the responses.

#### Diagnostic value of questionnaires and scales for UI

Several studies examined the diagnostic value of questionnaires and validated scales compared to multichannel video urodynamic testing, ^452,^ ^480,^ ^506,^ ^886^ – ^889^ physician diagnosis based on medical history, urine analysis, and micturition charts and diaries and urodynamics, ^447,^ ^890^ – ^892^ detailed interviews with nurses, ^893^ or other objective tests including the pad test, ^894^ provocative cough stress test, and computerized urethra-cystometrogram (Table 71). ^895^ One study tested a simple screening tool to detect common geriatric problems in community dwelling adults including UI. ^479^ The scales included questions on the presence and severity of symptoms of UI and quality of life. The majority of studies examined females only; three studies included both males and females. ^479,^ ^480,^ ^892^ An epidemiologic survey could identify only 56 percent of women who had urge UI and 66 percent of women who had stress UI. ^447^ Survey questions for geriatric UI could identify only 60 percent of incontinent adults. ^480^ The highest sensitivity of 98 percent was reported in a nonrandomized multicenter study of 531 patients with overactive bladder and urge UI detected with a simple, five-item questionnaire. ^892^

Table 71 Diagnostic value of validated questionnaires and scales to detect persons at risk and patients with UI

Author | Level of Evidence | UI Type | Index Test (Scale) | Gold Standard | Sensitivity (%) | Specificity (%) | Predictive Likelihood Ratio | NNS: Women
Sample
Moore, 1996 ^479^ | II-2 | Mixed | “Screen” | Blinded geriatricians' assessments | 89 | 95 | 17.80 | 5
N = 109; 66% female
Kirschner-Hermanns, 1998 ^480^ | II-2 | Stress | Questionnaire | Multichannel video urodynamic testing | 60 | 96 | 15.00 | 8
N = 132; 80% female
Sandvik, 1995 ^447^ | II-2 | Urge | Questionnaire | Physicians' diagnosis based on medical history, urine analysis, and micturition chart | 56 | 96 | 14.00 | 9
N = 250; 100% female | | Stress | Questionnaire | Physicians' diagnosis based on medical history, urine analysis, and micturition chart | 66 | 88 | 5.50 | 9
Seim, 2004 ^892^ | II-1 | Overactive bladder | Questionnaire | Physicians' diagnosis based on medical history, urine analysis, and micturition chart | 98 | 90 | 9.80 | 5
N = 531; 59% female
Rohr, 2004 ^893^ | II-2 | Stress | Questionnaire | Open interview | 91 | 86 | 6.50 | 5
N = 421; 100% female | | Urge | Questionnaire | Open interview | 91 | 86 | 6.50 | 2
Contreras Ortiz, 1993 ^886^ | II-2 | All | Bladder Instability Discriminant Index | Multichannel video urodynamic testing | 88 | 83 | 5.18 | 5
N = 217; 100% female
Bradley, 2005 ^891^ | II-2 | Urge | Questionnaire for Urinary Incontinence Diagnosis | Physicians' diagnosis based on medical history, urine analysis, a cough stress test, postvoid residual volume assessment, and multichannel urodynamic testing | 79 | 79 | 3.76 | 6
N = 117; 100% female | | Stress | Questionnaire for Urinary Incontinence Diagnosis | Physicians' diagnosis based on medical history, urine analysis, a cough stress test, postvoid residual volume assessment, and multichannel urodynamic testing | 85 | 71 | 2.93 | 6
Brown, 2006 ^890^ | II-2 | Urge | 3 incontinence questions | Physicians' diagnosis based on medical history, urine analysis, a cough stress test, postvoid residual volume assessment, and 3-day voiding diary | 75 | 77 | 3.26 | 6
N = 301; 100% female | | Stress | 3 Incontinence questions | Physicians' diagnosis based on medical history, urine analysis, a cough stress test, postvoid residual volume assessment, and 3-day voiding diary | 86 | 60 | 2.15 | 6
Gunthorpe, 2000 ^894^ | II-2 | Stress | Incontinence screening questionnaire | Pad test | 65 | 80 | 3.25 | 7
N = 89; 100% female
Klovning, 1996 ^887^ | II-2 | Stress | Detrusor instability score | Multichannel video urodynamic testing | 60 | 77 | 2.61 | 8
N = 250; 100% female
Lemack, 1999 ^888^ | II-1 | Stress | The Urogenital Distress Inventory (UDI-6) | Multichannel video urodynamic testing | 85 | 63 | 2.30 | 6
N = 128; 100% female
Fitzgerald, 2002 ^452^ | II-2 | All | The Urogenital Distress Inventory (UDI-6) | Multichannel video urodynamic testing | 88 | 55 | 1.96 | 5
N = 293; 100% female
Matharu, 2005 ^506^ | I | Urge | Questionnaire | Multichannel video urodynamic testing | 63.1 | 65.1 | 1.81 | 8
N = 490; 100% female | | Stress | Questionnaire | Multichannel video urodynamic testing | 76.9 | 56.3 | 1.76 | 6
Lemack, 1999 ^888^ | II-2 | Urge | The Urogenital Distress Inventory (UDI-6) | Multichannel video urodynamic testing | 83 | 50 | 1.66 | 6
N = 128; 100% female
Roongruangslip, 2005 ^889^ | II-2 | All | Questionnaire | Multichannel video urodynamic testing | 96 | 25 | 1.28 | 5
N = 129; 100% female
Kirschner-Hermanns, 1998 ^480^ | II-2 | Urge | Questionnaire | Multichannel video urodynamic testing | 84 | 21 | 1.06 | 8
N = 132; 80% female
Diokno, 1999 ^895^ | II-2 | Stress | MESA | Provocative cough stress test, post-void residual urine measurement, and computerized urethrocystometrogram | 62 | 100 | 62.00 | 8
N = 118; 100% female

NNS - number needed to screen or detect one case of UI

The sample size of the studies was not associated with the sensitivity of the scales to detect UI (Appendix Table F212). The specificity of the scales varied from 21 percent ^480^ to 100 percent. ^895^ The lowest specificity was demonstrated for a survey in elderly patients to detect urge UI. ^480^ The Medical, Epidemiologic, and Social Aspects of Aging Urinary Incontinence Questionnaire did not provide any false positive results of stress UI. ^895^ Such large variability in specificity of the scales could not be explained by differences in sample size (Appendix Table F212). The scales had comparable specificity for different types of UI; 95 percent for mixed UI, ^479^ 96 percent for stress UI, ^480^ and 96 percent for urge UI. ^447^

Three scales suggested a greater likelihood of UI compared to urodynamic evaluations ^480,^ ^895^ and physician diagnosis ^447,^ ^479^ (Appendix Table F213). The same scale resulted in larger positive likelihood ratios for urge (positive LR 14) and lower for stress UI (positive LR 5.5). ^447^ The majority of scales resulted in only a small (positive LR <4) probability of UI diagnosed with multichannel urodynamics, ^452,^ ^480,^ ^506,^ ^887^ – ^889^ pad test, ^894^ or physician diagnosis. ^890,^ ^891^ The moderate diagnostic value of the Urogenital Distress Inventory was reported in a systematic review with a pooled likelihood ratio of 2.2, 95 percent CI 1.5; 2.9. ^452,^ ^888^ Larger studies tended to report lower likelihood ratios, but the sample size could explain only small proportions of differences in ratios (Appendix Table F212). Across the studies, the consistent number needed to screen to detect one case of UI was two to three patients (Table 71).

Several studies estimated the validity of the questionnaires with correlation coefficients. One study of 384 older women reported a significant correlation (correlation coefficient ratio 0.2–0.7) between the Incontinence Impact Questionnaire and the Urogenital Distress Inventory with the clinical diagnosis of UI. ^896^ The Incontinence Severity Index was correlated with the 48-hour “pad weighing” test (correlation coefficient 0.6-0.6). ^875,^ ^897^

A large RCT reported a significant correlation between the Incontinence Quality of Life Questionnaire, Patient Global Impression of Improvement and Severity Questionnaire, and stress pad test results. ^507^ Secondary analyses of three clinical drug trials reported a significant correlation between the Urgency Perception Scale and patient voiding diary variables and other patient assessments, including perception of bladder condition, perception of treatment benefit, the Medical Outcomes Study Short-Form 36 health survey, the King's Health Questionnaire, the OAB Questionnaire, and the Overall Treatment Effect scale. ^898^ The significance of correlation coefficients depends on the sample size of the studies. For example, a large RCT reported a correlation coefficient ratio of 0.2–0.4 as significant. ^507^

In conclusion, two questionnaires demonstrated good diagnostic value compared to multichannel urodynamics to detect UI in epidemiologic surveys. ^447,^ ^895^ Two screening questionnaires may accurately detect UI in older adults. ^479,^ ^480^ Several questionnaires of severity and quality of life of UI that demonstrated rigorous validity and reliability were recommended for clinical practice and research. The clinical and economical value of self-reported perceived UI needs future research.

#### Diagnostic value of clinical history compared to multichannel urodynamic for stress UI in community dwelling adults

The diagnostic value of clinical history to detect stress UI compared to a “gold standard” multichannel urodynamics was examined in 24 studies with inconsistent results. ^435^ – ^455,^ ^899^ Most of the studies included females; one evaluated stress UI in men after radical prostatectomy ^899^ (Table 72). The authors used ICS criteria to define urodynamic UI, noted during filling cystometry as the involuntary leakage of urine during increased abdominal pressure, in the absence of a detrusor contraction. ^483^ Clinical history assessments varied but were poorly reported. The common assessment included duration and severity of involuntary urine leakage, exacerbating factors, baseline diseases, self management, and impact on quality of life.

Table 72 Diagnostic value of clinical history compared to multichannel urodynamics - “gold standard” to detect persons at risk and patients with UI

Author | True Positive | False Positive | False Negative | True Negative | Sensitivity (%) | Specificity (%) | Positive Predictive Value | Predictive Likelihood Ratio
Sample
Stress UI
Porru, 1994 ^435^ | | | | | 100 | 95 | | 20.00
N = 46; 100% female
Ishiko, 2000 ^436^ | 152 | 4 | 14 | 28 | 92 | 88 | 97 | 7.67
N = 198; 100% female
Yalcin, 2004 ^437^ | | | | | 44 | 87 | | 3.38
N = 1,455; 100% female
Diokno, 1990 ^438^ | 65 | 14 | 30 | 52 | 68 | 79 | 82 | 3.24
N = 456; 100% female
Ramsay, 1993 ^439^ | 72 | 28 | 19 | 81 | 79 | 74 | 72 | 3.04
N = 200; 100% female
Muylder, 1992 ^440^ | 228 | 58 | 14 | 108 | 94.2 | 65.1 | 80 | 2.70
N = 408; 100% female
Lagro-Janssen, 1991 ^441^ | 76 | 9 | 3 | 15 | 96 | 63 | 89 | 2.59
N = 103; 100% female
Clarke, 1997 ^442^ | | | | | 96 | 63 | | 2.59
N = 1,000; 100% female | | | | | 96.1 | 23.4 | | 1.25
| | | | | 70 | 35 | | 1.08
Sand, 1988 ^443^ | 114 | 43 | 0 | 66 | 100 | 61 | 73 | 2.56
N = 218; 100% female
Kujansuu, 1982 ^444^ | 46 | 20 | 11 | 43 | 81 | 68 | 70 | 2.53
N = 121; 100% female
Niecestro, 1992 ^445^ | 13 | 17 | 3 | 32 | 81 | 65 | 43 | 2.31
N = 66; 100% female
Sunshine, 1989 ^446^ | 73 | 14 | 0 | 15 | 100 | 52 | 84 | 2.08
N = 109; 100% female
Sandvik, 1995 ^447^ | 179 | 26 | 4 | 27 | 98 | 51 | 87 | 2.00
N = 785; 100% female
Ficazzola, 1998 ^899^ | | | | | 100 | 50 | | 2.00
N = 60; 0% female
Bergman, 1990 ^448^ | | | | | 56 | 70 | | 1.87
N = 154; 100% female
Weidner, 2001 ^449^ | | | | | 66 | 63 | | 1.78
N = 950; 100% female
Cundiff, 1997 ^450^ | 416 | 60 | 17 | 42 | 96 | 41 | 87 | 1.63
N = 535; 100% female
Le Coutour, 1990 ^451^ | | | | | 92 | 39 | | 1.51
N = 154; 100% female
Fitzgerald, 2002 ^452^ | 187 | 51 | 22 | 33 | 90 | 39 | 79 | 1.48
N = 293; 100% female
Korda, 1987 ^453^ | 451 | 39 | 52 | 24 | 90 | 38 | 92 | 1.45
N = 566; 100% female
Ouslander, 1987 ^454^ | 82 | 31 | 5 | 17 | 94 | 35 | 73 | 1.45
N = 135; 100% female
Diokno, 1987 ^455^ | 145 | 40 | 9 | 6 | 94 | 13 | 78 | 1.08
N = 200; 100% female
Urge UI
Ishiko, 2000 ^436^ | 25 | 6 | 4 | 154 | 86 | 96 | 81 | 21.50
N = 198; 100% female
Sand, 1988 ^443^ | 10 | 3 | 20 | 185 | 33 | 98 | 77 | 16.50
N = 218; 100% female
Sandvik, 1995 ^447^ | 23 | 8 | 18 | 187 | 56 | 96 | 74 | 14.00
N = 785; 100% female
Lagro-Janssen, 1991 ^441^ | 11 | 4 | 7 | 81 | 61 | 95 | 73 | 12.20
N = 103; 100% female
Cundiff, 1997 ^450^ | 42 | 17 | 60 | 416 | 41 | 96 | 71 | 10.25
N = 242; 100 % female
Yalcin, 2004 ^437^ | | | | | 41 | 96 | | 10.25
N = 1,455; 100% female
van Waalwijk van Doorn, 1997 ^903^ | | | | | 53 | 94 | | 8.83
N = 228; 100% female
Diokno, 1987 ^455^ | | | | | 14 | 97 | | 4.67
N = 200; 100% female
Fitzgerald, 2002 ^452^ | 10 | 21 | 27 | 235 | 27 | 92 | 32 | 3.38
N = 293; 100% female
Ouslander, 1987 ^454^ | | | | | 32 | 90 | | 3.20
N = 135; 100% female
Ficazzola, 1998 ^899^ | | | | | 50 | 77 | | 2.17
N = 60; 0% female
Digesu, 2003 ^905^ | | | | | 28 | 86 | | 2.00
N = 4,500; 100% female
Ding, 1997 ^904^ | | | | | 73 | 60 | | 1.83
N = 126; 0% female
Cantor, 1980 ^902^ | 107 | 53 | 11 | 43 | 91 | 45 | 67 | 1.65
N = 214; 100% female
Kong, 1990 ^901^ | | | | | 79 | 49 | | 1.55
N = 269; 100% female
Petros, 1992 ^900^ | | | | | 40 | 74 | | 1.54
N = 113; 100% female
Muylder, 1992 ^440^ | 147 | 91 | 89 | 81 | 62.3 | 47.1 | 62 | 1.18
N = 408; 100% female
Clarke, 1997 ^442^ | | | | | 68 | 12.9 | | 0.78
N = 1,000; 100% female
Mixed UI
Yalcin, 2004 ^437^ | | | | | 68 | 47 | | 1.28
N =1455; 100% female
Clarke, 1997 ^442^ | | | | | 91 | 23.8 | | 1.19
N = 1,000; 100% female

The sensitivity of the clinical history compared to multichannel urodynamics varied from 44 percent in the largest study ^437^ to 100 percent in several studies in females ^435,^ ^443,^ ^446^ and males. ^899^ The larger study tended to report lower sensitivity; 20 percent of the variation in sensitivity was attributable to sample size (Appendix Figure F2).

Specificity also varied substantially from 13 percent in a study with elderly women ^455^ to 95 percent in the smallest study of 46 patients with complaints of UI or voiding disorders. ^435^ The largest study of 1,455 women reported specificity of 87 percent. ^437^ Clinical history resulted in 50 percent false positive results in males. ^899^ The variability in specificity could not be explained by the sample size of the studies; only 3 percent was attributable to the number of subjects (Appendix Table F212). Positive predictive values as the proportion of true positives among all positives also varied from 66 percent in a study of 66 females ^445^ to 92 percent in a study of 566 patients. ^453^ Larger studies tended to report greater positive predictive values of clinical history (Appendix Figure F3); 22 percent of the differences in positive predictive values were attributable to the sample size of the study. Only one study of 46 women showed that clinical history was associated with a definite increase in the likelihood of disease (positive likelihood ratio of 20). ^435^ One study of 198 Japanese women reported a moderate increase in the likelihood of stress UI identified with clinical history compared to multichannel urodynamics (positive likelihood ratio of 7.7). ^436^ The majority of the studies found only small increases (positive likelihood ratios >2) in the likelihood of stress UI identified with clinical history ^440^ – ^447,^ ^899^ or minimal (positive likelihood ratios >1). ^442,^ ^448^ – ^455^ The differences in sample size could not explain the variability in positive likelihood ratios (Appendix Table F212). One systematic review reported a small positive likelihood ratio (2.09, 95 percent CI 1.83; 2.35) associated with the pooled sensitivity and specificity in females using studies published before 2003. ^867^ The review reported highly significant heterogeneity between studies (p<0.0001) in sensitivity and specificity with no clear explanations for substantial variability in diagnostic values of clinical history to detect stress UI.

#### Diagnostic value of clinical history compared to multichannel urodynamics for urge UI in community dwelling adults

The diagnostic value of clinical history to detect urge UI and detrusor overactivity compared to a “gold standard” multichannel urodynamic, was examined in 18 studies. ^436,^ ^437,^ ^440^ – ^443,^ ^447,^ ^450,^ ^452,^ ^454,^ ^455,^ ^899^ – ^905^ The majority of studies included females; two studies evaluated urge UI in men after radical prostatectomy ^899^ and in older males with persistent lower urinary tract symptoms. ^904^ The authors used the ICS criteria to define urodynamic urge UI during filling cystometry. ^483^ The sensitivity of clinical history to detect urge UI varied: it was 14 percent in one study of older women, ^455^ less than 50 percent in seven studies ^437,^ ^443,^ ^450,^ ^452,^ ^454,^ ^905^ to 50 to 80 percent in eight studies, ^440^ – ^442,^ ^447,^ ^899,^ ^901,^ ^903,^ ^904^ and more than 80 percent in two studies. ^436,^ ^902^ Large trials reported sensitivity of 28 percent ^905^ to 41 percent. ^437^ The sample size of the studies could explain only 7 percent of the differences in sensitivity (Appendix Table F212).

The specificity of clinical history varied from 13 percent in one comparative study of 1,000 females with lower urinary tract symptoms ^442^ to 45–80 percent in six studies, including two studies in men, ^440,^ ^899^ – ^902,^ ^904^ while the majority of the studies reported specificities greater than 85 percent. ^436,^ ^437,^ ^441,^ ^443,^ ^447,^ ^450,^ ^452,^ ^454,^ ^455,^ ^903,^ ^905^ Inconsistency in diagnostic values varied by study design to reduce bias in estimations. RCTs reported a specificity of 96 percent, ^437^ while a nonrandomized clinical trial of 4,500 women showed a lower specificity of 86 percent. ^905^ Substantial variability in specificity was not attributable to differences in sample size. Full cross-tabulations of the results were available in eight studies to calculate positive predictive values as the proportion of true positives among all positives that were detected with clinical history. One study in males reported the lowest positive predictive value (PPV) of 33 percent; ^452^ six studies showed PPV as 62 to 77 percent. ^440,^ ^441,^ ^443,^ ^447,^ ^450,^ ^902^ The highest PPV of 81 percent was reported in a comparative study of 198 Japanese women. ^436^ The sample size of the studies was not associated with differences in PPV. Several studies found that clinical history could increase the likelihood of urge UI with positive likelihood ratios between 10 and 22. ^436,^ ^437,^ ^441,^ ^443,^ ^447,^ ^450^ Two studies reported moderate probability of urge UI detected with clinical history with positive likelihood ratios between 5 and 9. ^455,^ ^903^ The majority of the studies showed only a small increase in likelihood of urge UI detected with clinical history. ^440,^ ^452,^ ^454,^ ^899^ – ^902,^ ^904,^ ^905^ One study of 1,000 women with symptoms of lower urinary tract dysfunction demonstrated a very low positive likelihood ratio of clinical history (<1) to diagnose urge UI. ^442^ Larger studies tended to report lower positive predictive likelihood, but only 2 percent of the variability was attributable to the sample size of the studies. A systematic review of eight studies reported a small positive likelihood ratio of 4.69, 95 percent CI 4.05 to 5.33 associated with the pooled sensitivity and specificity to detect detrusor overactivity and urge UI in females. ^867^ Heterogeneity between studies was significant (p<0.0001) with no well defined reasons for such variability in diagnostic value of clinical history.

Two studies examined the diagnostic value of clinical history to detect mixed UI and reported sensitivity from 68 percent ^437^ to 91 percent, ^442^ specificity from 47 percent to 24 percent respectively, and a small positive predictive likelihood of 1.3 or 1.2 respectively.

#### Diagnostic values of different tests to detect persons at risk and patients with UI

were examined in 23 studies with sample sizes varying from 20 ^906^ to 981 adults ^907^ (Appendix Table F214). The diagnostic value of the tests varied substantially, depending on index methods, populations, and type of UI. Sensitivity differed from a low of 25 percent to detect outlet obstruction in males with ambulatory compared to conventional urodynamic testing ^908^ to 100 percent to detect female urge UI with cystometry by fetal cardiotocographic monitor for pressure recording ^909^ or stress UI by the fluid bridge test. ^910^ Specificity was the lowest (7 percent) for ambulatory urodynamic monitoring compared to multichannel urodynamics to detect stress UI in female soldiers. ^911^ The majority of studies demonstrated specificity of the index tests less than 90 percent. The fluid bridge test had a 76 percent probability (specificity of 24 percent) of false positive results. Urethral pressure profile examination had a specificity of more than 90 percent in two studies. ^912,^ ^913^ Cough stress test and single-channel medium-fill cystometry ^914^ and cystometry using a fetal monitor ^909^ also had a low probability of false positive results for urge UI compared to multichannel urodynamics (specificity 96 percent). The Resident Assessment Protocol included in the MDS demonstrated a specificity of 97 percent to detect stress UI in 123 randomly selected residents of 13 nursing homes in five states compared to multichannel urodynamics with definitions adjusted for impaired contractility in elderly patients. ^481^ The positive likelihood ratio was defined as the ratio of the probability of a patient with UI having a positive test to the probability of an individual without UI having a positive test was 25.3 to diagnose significant stress leakage in residents of these nursing homes. ^481^ Several studies examined diagnostic values of the urethral pressure profile; one nonrandomized clinical trial of 108 women reported a large predictive likelihood of 24.5 to detect stress UI. ^913^ Results were inconsistent across the same comparisons in other studies with small ^915^ – ^917^ or moderate positive likelihood ^907,^ ^912^ to diagnose UI. The majority of studies showed that tested diagnostic methods provided only a small likelihood of UI in adults (Appendix Table F214).

The majority of the studies that examined the diagnostic value of x-ray compared to multichannel urodynamics reported a small positive likelihood ratio to detect UI (Appendix Table F215). ^456^ – ^459,^ ^461^ One large study of 1,584 males and females showed a likelihood ratio of 10.11 for micturating cystourethrography to detect UI. ^460^ The full bladder clinical stress test had a conclusive diagnostic value with a likelihood ratio of 33.5 in one study ^464^ and moderate likelihood ratios between 5 and 10 in three studies. ^465,^ ^918,^ ^919^ Single channel urodynamics demonstrated inconsistent diagnostic value for stress and urge UI with likelihood ratios varying from 1.9 in the geriatric population ^463^ to 24.5 in younger women. ^462^

#### Diagnostic value of ultrasound compared to UI in community dwelling adults

The diagnostic values of ultrasound exams to detect UI compared to multichannel urodynamics were examined in ten studies in community dwelling females to detect mixed ^470,^ ^473^ or stress UI ^471,^ ^472,^ ^474^ – ^477,^ ^920,^ ^921^ with no studies conducted in males (Table 73). One study of 201 incontinent nursing home residents, which examined a portable ultrasound device to diagnose post-void residual volume confirmed with catheterization, showed the lowest sensitivity of 59 percent to detect post-void residual volume >150ml. ^922^ The same study reported a high sensitivity of 95 percent to detect low post-void residual volume (<100ml). ^922^

Table 73 Diagnostic value of ultrasound exam compared to multichannel urodynamics - “gold standard” to detect persons at risk and patients with UI

Author | Ultrasound Criteria to Detect Risk of Incontinence | Sensitivity (%) | Specificity (%) | Positive Predictive Value (%) | Positive Predictive Likelihood
Sample
Jolic, 1997 ^920^ | Vaginal probe <22mm | | | 63
N = 66; 100% female | Vaginal probe <10mm | | | 72
| Abdominal probe | | | 93
Ouslander, 1994 ^922^ | Post-void residual urine volume <50ml | 90 | 71 | | 3.10
N = 201; 74% female | Post-void residual urine volume <100ml | 95 | 63 | | 2.57
| Post-void residual urine volume ≥50ml | 63 | 95 | | 12.60
| Post-void residual urine volume ≥150ml | 59 | 97 | | 19.67
| Post-void residual urine volume >200ml | 69 | 99 | | 69.00
Dietz, 1999 ^923^ | Fluid leakage | 63 | 86 | 77 | 4.50
N = 37; 100% female
Kuo, 1994 ^472^ | Bladder neck anatomy
N = 102; 100% female
Dietz, 1998 ^473^ | Bladder neck anatomy | 84 | 76 | 88 | 3.50
N = 125; 100% female
Dietz, 2001 ^470^ | Fluid leakage | 94 | 88 | 94 | 7.83
N = 52; 100% female
Quinn, 1989 ^471^ | Fluid leakage | 97 | 82 | 94 | 5.39
N = 124; 100% female
Chen, 1997 ^474^ | Bladder neck anatomy | 73 | 77 | 64 | 3.17
N = 65; 100% female
Bergman, 1988 ^475^ | Bladder neck anatomy | 86 | 96 | 95 | 21.50
N = 91; 100% female
Bergman, 1988 ^921^ | Bladder neck anatomy | 94 | 90 | 91 | 9.40
N = 61; 100% female
Kiilhoma, 1994 ^476^ | Bladder neck anatomy | 72
N = 38; 100% female
Huang, 2003 ^477^ | Bladder neck anatomy | 59.5 | 68.6 | 19.8 | 1.89
N = 320; 100% female

The studies used different ultrasound techniques and definitions of UI including transrectal ultrasound ^475,^ ^921^ to detect a drop in urethrovesical junction pressure during stress as a criterion for stress UI; translabial ^470,^ ^923^ or vaginal ^471^ ultrasound to observe urine leakage during the stress test; or perineal ultrasound to examine the opening of bladder neck and rotational angle. ^474,^ ^476,^ ^477^

Bladder neck funneling on ultrasonography had 60 percent sensitivity to detect low leak point pressure in a study of 320 women. ^477^ The highest sensitivity (>90 percent) was reported in two studies to observe urine leakage using translabial ^470^ or vaginal ultrasound. ^471^ Specificity ranged from 69 to 99 percent, depending on definitions of UI ^922^ and ultrasound techniques. ^470,^ ^471,^ ^474,^ ^475,^ ^921,^ ^923^ The PPV was lowest (19.8 percent) in a study to detect low leak point pressure in women with stress UI. ^477^ Three studies reported PPV >93 percent to detect urine leakage ^470,^ ^471^ or a drop in urethrovesical junction pressure. ^475^ An ultrasound exam with a portable device provided a definite diagnosis of post-void residual urine volume >200ml in nursing home residents with a positive likelihood ratio of 69. ^922^ Transrectal ultrasound conclusively detected a drop in urethrovesical junction pressure during stress tests in women with stress UI with a positive likelihood ratio of 21.5 ^475^ and in women undergoing surgery for stress urinary incontinence of 9.4. ^921^ Ultrasound findings of urine leakage were associated with a moderate probability of UI in two studies with positive likelihood ratios >5. ^470,^ ^471^ The differences in sample size could explain only 2 percent of the variability in likelihood ratios.

In conclusion, clinical history of UI results in a small likelihood of urodynamic UI and in a moderate likelihood of urodynamic urge UI in females. Very limited evidence in males suggests that clinical history of UI is not accurate to predict urodynamic UI. Inconsistent evidence implied that diagnostic values of x-ray, single channel urodynamic, full bladder clinical test, and Q-tip test are similar to multichannel urodynamics. Ultrasound diagnosis of urinary leakage and bladder neck anatomy was comparable to urodynamic UI and urinary retention in community dwelling adults and residents of nursing homes. MDS algorithms accurately diagnosed UI in LTC settings.

To assess the effectiveness of diagnostic methods to detect UI in adults, we estimated the number needed to screen to detect one case of UI and the number of diagnostic tests needed to detect one case of UI using the recently published prevalence of undiagnosed UI in age, gender, race, and socioeconomic status categories. ^146^ The cost of different procedures was obtained from the systematic review and cost-effectiveness analysis of diagnostic tests of UI. ^867^ Despite substantial differences in positive predictive likelihood ratios, the number needed to screen and the number of needed tests was similar and consistent among the studies (Table 74). Epidemiologic surveys with self-completed scales and questionnaires would cost less than $70 to detect one case of UI. The professional assessment of clinical history would cost from $175 in males after radical prostatectomy ^899^ to nearly $400 in women with stress UI. ^437^ Health care providers would need to collect clinical history in five to 15 patients to detect one case of urodynamic UI; the cost would not be more than $250. Clinical history had the lowest cost to diagnose urge UI in males with persistent lower urinary tract symptoms ^904^ and the highest cost to detect detrusor overactivity in elderly women. ^455^ The detection of urge UI with professional assessment of clinical history would cost more than $300 in the majority of the studies. The cost of ultrasound exams to detect one case of urodynamic UI varied from $600 to $900. The effectiveness of self-reported scales, professional assessment of clinical history, and ultrasound to detect UI in women was comparable and consistent across race, age, and socioeconomic groups; one to four women should be examined to detect one case of UI (Table 75). The number needed to screen males to detect one case of UI was also consistent in population groups (Appendix Table F216). The cost of different treatment options was beyond present analysis but may affect the cost of diagnostic pathways. One of the most expensive diagnostic methods, multichannel urodynamic evaluation, is an important step to diagnose intrinsic sphincter deficiency (urodynamic urinary incontinence and a maximum urethral closure pressure ≤20cm H_2_O ) in combination with hypermobility in women planning surgery for stress UI. ^924^ However, this costly invasive examination may not be necessary for women who prefer behavioral treatments including lifestyle changes, bladder training, and pelvic floor muscle training. The effects of population-based screening and educational programs on clinical outcomes, quality of life, and cost of available treatments need future investigations in well designed RCTs.

Table 74 Number needed to screen to detect one case of UI, number of tests to detect one case of UI, and cost to detect one case of UI (prevalence of undiagnosed UI ^146^ and cost of diagnostic tests ^867^ )

Author | Positive Likelihood Ratio | Number Needed to Screen to Detect One Case of UI | Number of Tests to Detect One Case of UI | Cost to Detect One Case ($)
| | | | Cost of Screening to Detect One Case of UI | Costs of Tests to Detect One Case of UI
Scales to Diagnose UI
Moore, 1996 ^479^ | 17.8 | 5 | 2 | 40.63 | 16.62
Kirschner-Hermanns, 1998 ^480^ | 15.0 | 8 | 2 | 60.27 | 16.92
| 1.1 | 8 | 6 | 60.02 | 45.02
Sandvik, 1995 ^447^ | 14.0 | 9 | 2 | 64.58 | 17.05
| 5.5 | 9 | 2 | 67.53 | 17.05
Seim, 2004 ^892^ | 9.8 | 5 | 2 | 36.90 | 17.93
Rohr, 2004 ^893^ | 6.5 | 5 | 3 | 39.74 | 19.42
Contreras Ortiz, 1993 ^886^ | 5.2 | 5 | 3 | 37.52 | 19.42
Bradley, 2005 ^891^ | 3.8 | 6 | 3 | 45.02 | 22.51
| 2.9 | 6 | 3 | 45.02 | 22.51
Brown, 2006 ^890^ | 3.3 | 6 | 3 | 45.02 | 24.57
| 2.2 | 6 | 3 | 45.02 | 26.12
Gunthorpe, 2000 ^894^ | 3.3 | 7 | 4 | 52.52 | 27.67
Klovning, 1996 ^887^ | 2.6 | 8 | 4 | 60.02 | 29.21
Lemack, 1999 ^888^ | 2.3 | 6 | 4 | 45.02 | 30.01
| 1.7 | 6 | 4 | 45.02 | 30.81
Fitzgerald, 2002 ^452^ | 2.0 | 5 | 4 | 37.52 | 31.61
Matharu, 2005 ^506^ | 1.8 | 8 | 4 | 60.02 | 32.41
| 1.8 | 6 | 4 | 45.02 | 33.21
Roongruangslip, 2005 ^889^ | 1.3 | 5 | 5 | 37.52 | 34.01
Diokno, 1999 ^895^ | 62.0 | 8 | 2 | 60.02 | 15.01
Clinical History to Diagnose Stress UI
Porru, 1994 ^435^ | 20.0 | 5 | 2 | 175.22 | 77.73
Ishiko, 2000 ^436^ | 7.7 | 5 | 2 | 190.46 | 85.81
Yalcin, 2004 ^437^ | 3.4 | 11 | 3 | 398.23 | 102.37
Diokno, 1990 ^438^ | 3.2 | 7 | 3 | 257.68 | 103.72
Diokno, 1987 ^455^ | 1.1 | 5 | 5 | 186.40 | 165.64
Ramsay, 1993 ^439^ \| | 3.0 | 6 | 3 | 221.80 | 105.75
DeMuylder, 1992 ^440^ | 2.7 | 5 | 3 | 186.01 | 109.91
Lagro-Janssen, 1991 ^441^ | 2.6 | 5 | 3 | 182.52 | 111.41
Clarke, 1997 ^442^ | 2.6 | 5 | 3 | 182.52 | 111.41
| 1.3 | 5 | 4 | 182.33 | 152.74
| 1.1 | 7 | 5 | 250.31 | 165.94
Sand, 1988 ^443^ | 2.6 | 5 | 3 | 175.22 | 111.87
Kujansuu, 1982 ^444^ | 2.5 | 6 | 3 | 216.32 | 112.38
Niecestro, 1992 ^445^ | 2.3 | 6 | 3 | 216.32 | 116.09
Sunshine 1989 ^446^ | 2.1 | 5 | 3 | 175.22 | 120.90
Sandvik, 1995 ^447^ | 2.0 | 5 | 3 | 178.80 | 122.91
Ficazzola, 1998 ^899^ | 2.0 | 5 | 3 | 175.22 | 122.91
Bergman, 1990 ^448^ | 1.9 | 9 | 3 | 312.89 | 126.50
Weidner, 2001 ^449^ | 1.8 | 7 | 4 | 265.48 | 129.00
Cundiff, 1997 ^450^ | 1.6 | 5 | 4 | 182.52 | 134.42
Le Coutour, 1990 ^451^ | 1.5 | 5 | 4 | 190.46 | 139.28
Fitzgerald, 2002 ^452^ | 1.5 | 5 | 4 | 194.69 | 140.76
Korda, 1987 ^453^ | 1.5 | 5 | 4 | 194.69 | 141.88
Ouslander, 1987 ^454^ | 1.4 | 5 | 4 | 186.40 | 142.14
Clinical History to Diagnose Urge UI
Ishiko, 2000 ^436^ | 21.5 | 6 | 2 | 203.74 | 77.38
Sand, 1988 ^443^ | 16.5 | 15 | 2 | 530.97 | 78.79
Sandvik, 1995 ^447^ | 14.0 | 9 | 2 | 312.89 | 79.88
Lagro-Janssen, 1991 ^441^ | 12.2 | 8 | 2 | 287.25 | 80.94
Cundiff, 1997 ^450^ | 10.3 | 12 | 2 | 427.36 | 82.50
Yalcin, 2004 ^437^ | 10.3 | 12 | 2 | 427.36 | 82.50
Van Waalwijk van Doorn, 1997 ^903^ | 8.8 | 9 | 2 | 330.60 | 84.08
Diokno, 1987 ^455^ | 4.7 | 34 | 3 | 1251.57 | 94.22
Fitzgerald, 2002 ^452^ | 3.4 | 18 | 3 | 648.96 | 102.46
Ouslander, 1987 ^454^ | 3.2 | 15 | 3 | 547.56 | 104.09
Ficazzola, 1998 ^899^ | 2.2 | 10 | 3 | 350.44 | 118.90
Digesu, 2003 ^905^ | 2.0 | 17 | 3 | 625.78 | 122.91
Ding, 1997 ^904^ | 1.8 | 7 | 4 | 240.03 | 127.73
Cantor, 1980 ^902^ | 1.7 | 5 | 4 | 192.55 | 133.39
Kong, 1990 ^901^ | 1.5 | 6 | 4 | 221.80 | 137.53
Petros, 1992 ^900^ | 1.5 | 12 | 4 | 438.05 | 137.97
DeMuylder, 1992 ^440^ | 1.2 | 8 | 4 | 281.25 | 157.97
Clarke, 1997 ^442^ | 0.8 | 7 | 6 | 257.68 | 201.32
Clinical History to Diagnose Mixed UI
Yalcin, 2004 ^437^ | 1.3 | 7 | 4 | 257.68 | 150.97
Clarke, 1997 ^442^ | 1.2 | 5 | 4 | 192.55 | 156.79
Ultrasound to Diagnose UI
Ouslander, 1994 ^922^ | 3 | 5 | 3 | 602.39 | 325.07
| 3 | 5 | 3 | 570.68 | 345.97
| 13 | 8 | 2 | 860.55 | 249.63
| 20 | 8 | 2 | 918.90 | 240.77
| 69 | 7 | 2 | 785.72 | 229.47
Dietz, 1999 ^923^ | 5 | 8 | 3 | 860.55 | 294.01
Dietz, 1998 ^473^ | 4 | 6 | 3 | 645.42 | 313.73
Dietz, 2001 ^470^ | 8 | 5 | 2 | 576.75 | 264.63
Quinn, 1989 ^471^ | 5 | 5 | 3 | 558.92 | 282.62
Chen, 1997 ^474^ | 3 | 7 | 3 | 742.67 | 322.85
Bergman, 1988 ^475^ | 22 | 6 | 2 | 630.41 | 239.42
Bergman, 1988 ^921^ | 9 | 5 | 2 | 576.75 | 258.02
Kiilhoma, 1994 ^476^ | | 7 | 6 | 752.98 | 656.45
Huang, 2003 ^477^ | 2 | 8 | 3 | 911.17 | 388.92

Number needed to screen to identify one undiagnosed incontinence case = [(prevalence of undiagnosed incontinence) (sensitivity of the diagnostic method)] -1.

Number of diagnostic tests to identify one undiagnosed incontinence case = 2 + number needed to screen (1 - prevalence of undiagnosed incontinence) (1 - specificity of the diagnostic test) ^925^ .

Table 75 Number needed to screen and number of tests to detect one case of UI in women (pooled sensitivity and sensitivity of tests in comparison with multichannel urodynamic ^867^ )

Prevalence of Undiagnosed UI | | Clinical History to Diagnose Stress UI | | Clinical History to Diagnose Urge UI | | Ultrasound to Diagnose Stress UI | | Scales to Diagnose Stress UI
Population Categories | | Number Needed to Screen | Number of Tests | Number Needed to Screen | Number of Tests | Number Needed to Screen | Number of Tests | Number Needed to Screen | Number of Tests
All | 0.55 | 5 | 4 | 8 | 3 | 5 | 3 | 6 | 4
Race/Ethnicity
Black | 0.66 | 4 | 3 | 7 | 3 | 4 | 3 | 5 | 3
Hispanic | 0.41 | 7 | 5 | 11 | 3 | 7 | 3 | 7 | 4
White | 0.52 | 6 | 4 | 8 | 3 | 6 | 3 | 6 | 4
Age Group
30–39 | 0.84 | 7 | 5 | 10 | 3 | 7 | 3 | 7 | 4
40–49 | 0.46 | 10 | 6 | 15 | 4 | 10 | 4 | 10 | 6
50–59 | 0.43 | 10 | 6 | 16 | 4 | 11 | 4 | 11 | 6
60–79 | 0.50 | 8 | 5 | 12 | 3 | 8 | 3 | 8 | 5
Socioeconomic Status
Low | 0.44 | 7 | 4 | 10 | 3 | 7 | 3 | 7 | 4
Middle | 0.56 | 5 | 4 | 8 | 3 | 5 | 3 | 5 | 4
High | 0.57 | 5 | 4 | 8 | 3 | 5 | 3 | 5 | 4
Medical Insurance
Any private | 0.57 | 5 | 4 | 8 | 3 | 5 | 3 | 5 | 4
Public only | 0.52 | 6 | 4 | 8 | 3 | 6 | 3 | 6 | 4
None | 0.55 | 5 | 4 | 8 | 3 | 5 | 3 | 6 | 4

Number needed to screen to identify one undiagnosed incontinence case = [(prevalence of undiagnosed incontinence) (sensitivity of the diagnostic method)] -1.

Number of diagnostic tests to identify one undiagnosed incontinence case = 2 + number needed to screen (1 - prevalence of undiagnosed incontinence) (1 - specificity of the diagnostic test) ^925^

### Strategies to Improve the Identification of Persons at Risk and Patients who have FI

The diagnostic pathway to detect persons at risk and patients with FI includes self-reported symptoms using questionnaires and scales, ^866^ clinical history of patients seeking help, anal manometry, sensory testing, anal endosonography, magnetic resonance imaging, and colonoscopy to detect baseline causes for FI. ^17^ Treatment decisions are made based on instrumental methods including ultrasound and anal manometry, but no consensus exists about which test is a “gold standard,” essential to estimate the diagnostic values of other tests. ^926^ Treatment decisions are made based on clinical assessments and functional and anatomical evaluations of the anorectum. ^17^

The Symptom and Quality of Life Committee of the International Consultation on Incontinence could not find sufficient evidence of psychometric properties to attain grade A status for the questionnaires and scales for FI and related quality of life (Appendix Table F217). ^866^ However, three questionnaires were recommended for evaluation of patients with FI, including the Fecal Incontinence Quality of Life Scale; ^484^ the Manchester Health Questionnaire, ^927^ and the Birmingham Bowel and Urinary Symptoms Questionnaire ^928^ (Appendix Table F218) The questionnaires assess the presence and severity of FI and the perceived quality of life including role and physical limitations, emotional impact of FI, personal relationships, and sexual restrictions related to FI. The American College of Gastroenterology Practice Parameters Committee advised using the Cleveland Clinic Grading system to evaluate the degree of incontinence and the efficacy of therapy, ^17^ but this was not recommended by the ICI committee. These guidelines do not provide sensitivity, specificity, or likelihood of FI as criteria to grade scales or to recommended questionnaires for research.

Very few studies examined the diagnostic values of scales to detect FI compared to physician diagnosis. The Epidemiology of Prolapse and Incontinence Questionnaire demonstrated 87 percent sensitivity, 70 percent specificity, 61 percent positive predictive value, and a small predictive likelihood ratio (2.9) to diagnose FI in 294 enrolled women with pelvic floor prolapse compared to examiner diagnosis. ^929^ The Bowel Symptom Questionnaire had a 48.5 percent sensitivity, a 79.2 percent specificity, a 43.2 percent positive predictive value, and a small likelihood ratio (2.3) to identify anal sphincter trauma related to vaginal delivery in 156 women. ^930^ The Bowel Symptom Questionnaire detected 57.1 percent of the cases of external anal sphincter disruption with specificity of 75.8 percent, positive predictive value of 21.6 percent, and positive likelihood ratio of 2.4. ^930^

The American College of Gastroenterology Practice Parameters Committee described a detailed algorithm to evaluate patients with FI or risk factors of FI. However, diagnostic values of the recommended tests were not well documented. For example, when health care professionals did not actively ask questions about continence status, routine clinical history and physical examination identified only 8 percent of patients with constipation and 11 percent with FI, compared to complex diagnostic methods including anal manometry, cinedefecography, electromyography of the anal sphincter, and assessment of terminal motor latency of the pudendal nerve. ^931^ Self reported and professional evaluations of severity and quality of life related to FI showed agreement in a study of 118 patients with FI. ^515^ However, surgeons defined solid incontinence as more severe, while patients assigned more severity scores to liquid FI. Clinical values and the economical cost of self-reported questionnaires to detect patients with undiagnosed incontinence require future research.

Anal manometry with an asymmetry index >25 percent had an 81 percent sensitivity, 71 percent specificity, and only a 2.8 positive likelihood ratio to predict combined anal sphincter defect detected with ultrasonography in 61 women with previous vaginal delivery and no past anoperineal surgery. ^932^ Anal manometry compared to endoanal ultrasonography in patients with idiopathic FI with intact sphincters had different diagnostic value for manometry outcomes. Abnormal resting pressure gradient (<1.78) had 89 percent sensitivity, 96.3 percent specificity, and a large predictive likelihood ratio of 24 to identify FI; maximal mean resting pressure (<40mmHg) had 55 percent sensitivity, 98 percent specificity, and a predictive likelihood ratio of 22, while vector volume (<11.8) had 53 percent sensitivity, 88 percent specificity, and a small predictive ratio of 4.3. ^933^ A combination of anal manometry and the strength-duration curve had better diagnostic values than tests alone with sensitivity of 95 percent and specificity of 100 percent to predict female FI due to sphincter weakness. ^934^ Abnormal anal pressure identified only 70 percent of incontinent patients with 68 percent specificity and a 2.5 predictive ratio. Strength duration data demonstrated 77 percent sensitivity and 84 percent specificity with a predictive value of 4.8. ^934^ Anal manometry with low squeeze sphincter pressure had 52 percent sensitivity to detect FI, impaired rectal sensation could identify only 36 percent incontinent patients; pudendal neuropathy was present in 50 percent of patients with FI diagnosed by colonoscopy or sigmoidoscopy. ^935^ Anal manometry, rectal capacity measurement, and saline-infusion tests did not demonstrate significant association with FI and could not differentiate 350 incontinent and 80 continent patients. ^936^

Endoanal ultrasound had 100 percent specificity and sensitivity to detect external sphincter defects and 100 percent sensitivity, 95 percent specificity, and a 20 predictive likelihood ratio to identify internal sphincter defects compared to morphological surgical findings in 40 women 26–80 years old with FI undergoing pelvic floor repair. ^482^

Endoanal magnetic resonance had 56 percent sensitivity, 69 percent specificity, 71 percent predictive positive value, and a 1.8 predictive likelihood ratio to detect defects of anal sphincter compared to endoanal ultrasonography in 237 patients with FI undergoing anal sphincter repair. ^937^ Endoanal ultrasonography identified 90 percent of external anal sphincter defects with an 85 percent positive predictive value compared to surgical findings. Endoanal magnetic resonance detected 81 percent of external anal sphincter defects with 40 percent specificity, 89 percent positive predictive value, and a small 1.3 positive likelihood ratio. ^937^

In conclusion, self-reported questionnaires and scales have unsatisfactory diagnostic clinical validity to diagnose anatomical or physiological causes of FI in adults. For tools using summary scores or scales, different ones are needed for FI and AI since these problems are defined differently. Anal ultrasonography has the highest diagnostic value to detect anal trauma in patients with FI. Patient complaints about FI assessed with a clinical history should be followed by the diagnostic procedures to diagnose primary conditions that may result in FI. Future research is needed to determine effective strategies to identify patients at risk of FI, including residents of LTC facilities.