# Methods

## Literature Search Strategy and Eligibility Criteria

### Search Strategy

Studies were sought from a wide variety of sources, including MEDLINE^®^ via PubMed^®^, CINAHL, Cochrane databases, and manual searches of reference lists from systematic reviews and the proceeding of the International Continence Society (ICS). The search strategies for the four research questions are described in Appendix B. Excluded references are shown in Appendix C. All work was conducted under the guidance of a Technical Expert Panel (TEP), whose members are identified in Appendix D.

### Eligibility

Three investigators independently decided on the eligibility of the studies according to recommendations from the Cochrane manual for systematic reviews. ^560^ The algorithm to define eligibility of the studies was developed for each research question (Appendix A). We reviewed abstracts to exclude secondary data analysis, reviews, letters, comments, and case reports. Then we confirmed eligible target populations of adults in community and LTC settings. The full texts of the original epidemiologic studies published in English after 1989 were examined to include studies with eligible outcomes defined as prevalence and incidence of incontinence, absolute and adjusted relative risk of incidence, and progression of urinary, fecal, and combined incontinence (operational definitions in Appendix A). We also developed a list of risk factors for UI and FI for Question 2 (operational definitions of known risk factors of UI and FI in Appendix A). For Question 3, we included studies that examined the effects of clinical interventions (operational definitions of clinical interventions for the primary and secondary prevention of incontinence in Appendix A). For Question 4, we included studies that evaluated different strategies to detect patients with incontinence and persons at risk. Then we excluded studies that did not test the associative hypotheses and did not provide adequate information on tested hypotheses (e.g., least square means, relative risk).

Finally, we confirmed eligible levels of evidence for each research question. The following inclusion criteria were applied to select articles for full review: For questions of prevalence and risk factors of incontinence in large population-based cross-sectional analyses and cohort studies, large cross-sectional analyses and cohorts in LTC settings, case-control studies with randomly selected controls and case series with more than 100 subjects were selected. For the question on clinical interventions to reduce the risk of UI and FI, we selected randomized controlled clinical trials and multicenter nonrandomized clinical trials (fecal and combined incontinence). For the question on strategies to detect incontinence, we selected randomized controlled clinical trials, multicenter controlled clinical trials, large (>100 subjects) observational studies, and case-control studies with >10 cases that reported sensitivity, specificity, and reliability of different diagnostic methods.

The exclusion criteria included the following:

- Studies with target population as children and adolescents
- Studies with no information relevant to incidence and progression of incontinence
- Studies that examined the distribution of different types of incontinence among incontinent patients (all incontinent in denominator)
- Studies that evaluated the association between incontinence as independent variables in association with other patient outcomes
- Case series with small numbers of cases and no control comparison
- Studies that reported absolute values of the diagnostic tests in incontinent patients
- Studies that did not report true and false positive and negative cases of diagnostic tests
- Observational studies and nonrandomized clinical trials that examined treatments in incontinent patients and short term (less than 1 year of followup) drug trials that did not report continence rates

### Quality Assessment and Rating the Body of Evidence

Study quality was analyzed using the following criteria: subject selection, length and loss of followup, adjustment for confounding factors in observational studies and intention to treat principle in clinical trials, masking the treatment status, randomization scheme and adequacy, allocation concealment, and justification of sample sizes in RCTs. ^561^

The level of evidence for all studies was estimated using a subset of the U.S. Preventive Services Task Force criteria noted below. ^562^

I: Properly designed randomized controlled trial

II-2A: Well-designed cohort (prospective) study with concurrent controls and multivariate analysis of the associations

II-2B: Well-designed cohort (prospective) study with historical controls and multivariate analysis of the associations

II-2C: Well-designed cohort (retrospective) study with concurrent controls and multivariate analysis of the associations

II-3: Well-designed case controlled (retrospective) study and multivariate analysis of the associations

III: Large differences from comparisons between times and/or places with or without interventions (cross-sectional comparisons).

For all questions, evidence tables were developed identifying the purpose of the study, sample, design, independent and dependent variables, and findings. For Questions 1, 2, and 3, incidence and prevalence cases of incontinence, relative risk of incontinence in categories of risk factors and clinical interventions, and outcomes level to assess severity and progression of incontinence for treatment differences were abstracted. ^563,^ ^564^ Baseline data were compared in different studies to test differences in the target population and unusual patterns in the data. ^565,^ ^566^ Standard deviations, regression coefficients, and 95 percent CI were calculated from reported means, standard errors, and sample size. ^563,^ ^564^ The protocol for the meta-analyses was created according to recommendations for meta-analysis of randomized controlled trials: the QUOROM statement. ^567^

### Applicability

Applicability of the population was estimated by evaluating the selection of the subjects in observational studies and clinical trials. ^568^ Large observational cohorts based on national registries, population-based surveys, and nationally representative administrative and clinical databases had high applicability. We compared the differences in prevalence of incontinence in studies that selected subjects from administrative and clinical databases and that reported random and convenience sampling of participants. ^569^ Applicability of the intervention duration was high for studies with followup 1 year or more and acceptable for studies with followup of 6–12 months.

We assumed the presence of publication bias and did not use statistical tests for bias defined as the tendency to publish positive results and to predict association when all conducted (published and unpublished) studies are analyzed. ^560,^ ^570^ – ^572^ We used several strategies to reduce bias, including comprehensive literature search of published and unpublished evidence in several databases the reference lists of systematic reviews and proceedings of the ICS, contacts with experts for additional references they might provide, and agreement on the eligibility status by several investigators.

### Data Extraction

Evaluations of the studies and data extraction were performed manually and independently by three researchers. The data abstraction forms are shown in Appendix E. Errors in data extractions were assessed by a comparison with the established ranges for each variable and the data charts with the original articles. Any discrepancies were detected and discussed. Patient populations were classified as community and LTC settings. Adjustments for patient age, race, gender, comorbidities, socioeconomic status, provider characteristics, and clustering of patients and providers were extracted from the studies. The details on extracted variables are presented in the analytic framework in Appendix A.

### Data Synthesis

For Questions 1 and 2, results of individual studies (expressed as crude and adjusted for confounding factors) were summarized in evidence tables to analyze differences in incontinence in categories by subject age, race, ethnicity, residency, and risk factors.

#### Definitions of incontinence

We analyzed separately urinary, fecal, and combined incontinence. We used the definitions of signs and symptoms of UI promoted by the ICS (Appendix A) including mixed, stress, and urge incontinence. We defined anal incontinence (AI) as involuntary loss of flatus, liquid, or solid stool. In the text we used the term FI and in the tables clarified the operational definitions of anal (flatus and fecal), FI, solid, or liquid incontinence, or its combinations. Continence was defined as self-reported absence of involuntary urine or feces loss. We defined combined incontinence as a combination of urine and fecal incontinence. When the authors reported prevalence of UI or FI but not combined incontinence in the same populations, we define the outcomes as UI only or FI only without additional assumption about possible misclassification. We also analyzed urinary continence defined as negative stress and pad tests. We used the term “urodynamic UI” to replace the older term “genuine stress incontinence.” Frequency of UI or FI was abstracted as daily, weekly, or monthly episodes of urine leakage or feces loss. Severity of UI was defined using the objectively measured urine loss in pad weight tests or self-reported pad use. Severity of FI was defined as self-reported amount of feces loss and pad use. Wet status in nursing home residents was analyzed to define severity of incontinence and effects of the treatments. We classified residents who needed indwelling urinary catheters and an external urinary drainage device as having severe or always UI. Restriction of daily activities, and perceived quality of life with UI or FI were defined using scales and composite scores.

#### Definitions of outcomes

We defined prevalence of incontinence as the probability of experiencing incontinence within a defined population and at a defined time point. ^20,^ ^21^ We defined true population incidence as newly diagnosed cases of incontinence that developed annually in the target population. True population incidence estimates were derived from large population-based surveys. However, for Question 3 we defined incidence as the probability of developing incontinence under study after active and control interventions during time of followup. ^20,^ ^21^ We defined reported incontinence as the prevalence of total incontinence or episodes of different types of incontinence when the authors did not access continence status as baseline or did not exclude prevalence cases from overall estimation

The absolute risk of incontinence among patients with rare risk factors was compared to the general population when no other evidence was available to estimate the adjusted relative risk.

For Question 3, relative risk (RR) and 95 percent confidence intervals (CIs) and differences in outcomes were calculated.

Patient outcomes (clinical events). We report both incidence and progression of incontinence as they were used by the authors of the original studies and with calculated rates of cure, improvement, and progression for purposes of comparison:

1 the number of patients that developed newly diagnosed incontinence (incidence cases) or the number of incontinent patients after active and control interventions (prevalence cases)
2 the number of patients cured by the clinical interventions
3 the number of patients with improved continence
4 the number of patients with progression defined as failure to cure or improve and increase in frequency and severity of incontinence.

Relative risk/odds ratio of developing incontinence was analyzed in the studies that reported incident cases. Relative risk/odds ratio of incontinence was analyzed in the studies that reported prevalence cases. Relative benefit of continence was defined as the likelihood of continence in patients after active treatment relative to those after control interventions. We defined relative benefit of improvement as a likelihood of improved incontinence in patients after active treatment relative to those after control interventions. We defined relative risk of progression of incontinence as the likelihood of increasing frequency and severity of incontinence and failure to cure/improve incontinence in patients after active treatment relative to those after control interventions

We analyzed continence separately from improvement in incontinence because continence is the most clinically desirable patient outcome and is well defined, whereas improvement can include substantial differences in definitions and changing perceptions of qualitative and quantitative parameters of improvement. We used such conservative approaches to generate precise estimates of the effectiveness. Clinicians and patients can make informed decisions based on the treatments that resulted in greater rates of long-term continence in well designed randomized controlled trials (RCTs).

We compared the effectiveness of different clinical interventions in relation to baseline rates of incontinence, assuming undiagnosed incontinence when the authors did not report objective assessment of continence status at baseline. We defined the clinical intervention to reduce the risk of incontinence (primary prevention) when the investigators selected the subjects in clinical trials by underlying condition, not by continence status. We defined clinical intervention to reduce the progression of incontinence when incontinent patients were invited to participate in clinical trials (secondary prevention).

For surgical interventions that aimed to treat the baseline conditions, including prolapse, cancer, ulcerative colitis, hemorrhoids, and anal fissures, incontinence was analyzed as the secondary outcome. The goal of the present review was to compare rates of incontinence after such procedures rather than review other therapeutic effects on baseline diseases or all complications of surgery.

Continuous outcomes (surrogates). We defined subjective continuous outcomes as the number of incontinent episodes, use of supplies, and scores from validated scales to analyze the quality of life with incontinence. We defined objective continuous outcomes as the results of objective tests to measure the severity of incontinence.

Pooling criteria included the same operational definitions of incontinence outcomes and the same risk factors or clinical interventions. ^573^ Homogeneity in clinical interventions was analyzed comparing published information on behavioral, instrumental (devices), pharmacological, and surgical treatments. Meta-analysis was used to assess the consistency of the association between treatments and incontinence outcomes with random effects models. ^574^ The analyses were conducted separately for symptoms and signs of incontinence. Assumptions underlying meta-analysis included valid measurements of continence status and similarity in study and target populations.

Consistency in the results was tested comparing the direction and strength of the association. Chi squared tests were used to assess heterogeneity in study results. ^575,^ ^576^ Significant heterogeneity means the effects of interventions on UI were not consistent in the studies (not replicable results). We explored heterogeneity with meta-regression and sensitivity analysis and reported the results from random effects models only. The analytic framework and algorithms for the meta-analysis are shown in Appendix A. Calculations were performed using STATA software at the 95 percent confidence level. ^577^

For Question 4 we calculated positive predictive value, predictive likelihood ratio, number needed to screen to diagnose one case of incontinence, and number of diagnostic tests needed to detect one case of incontinence (Appendix A). Cost-effectiveness of diagnostic methods was estimated by comparing the cost and number needed to screen and the number of diagnostic tests using different tests.