# Introduction

## Overview

Urinary (UI) and fecal (FI) incontinence affect substantial proportions of adults in different population groups. ^20^ Baseline mechanisms of UI include hyperactive bladder that may result in urge UI and poor urethral sphincter function that can result in primary urethral incompetence and stress UI. ^22,^ ^23^ Loss of structural and functional integrity of pudendal nerve activity, pelvic floor muscles, rectal compliance and rectal sensation, and the anal sphincter may result in FI. ^17,^ ^20,^ ^23,^ ^24^ The differences in baseline mechanisms of incontinence lead to variable definitions of UI and FI, some specific for each type of incontinence risk factors, and effective interventions to prevent and treat UI and FI. ^17,^ ^23,^ ^24^ The estimated prevalence of UI in adults was 9 to 22 percent ^8,^ ^9,^ ^30,^ ^35^ – ^38^ but varies widely as a result of differences in definitions and sampled populations subgroups. ^18^ For example, recent studies reported that 25 percent of young women, ^516^ 44 percent ^148^ to 57 percent of middle-age and post-menopausal women, ^93^ and 75 percent of elderly females in nursing homes ^32^ experienced some degree of involuntary urine loss. UI is prevalent among women of all races, though the magnitude, severity, and bother may vary; 41 percent of White women, 20 percent of African-American women, and 36 percent of Hispanic women reported difficulties controlling their bladders. ^18^ The severity of incontinence influences quality of life and treatment decisions. In the 1999-2000 National Health and Nutrition Examination Survey, 32 to 51 percent of women experienced daily episodes of UI and 20 to 32 percent experienced weekly episodes. ^9^ The prevalence of UI in men varied from 11 percent among those 60–64 years old to 31 percent in older males, and from 16 percent among White men to 21 percent among African American men. ^8^ Daily incontinence was reported by 30 to 47 percent and weekly incontinence by 15 to 37 percent of community dwelling men ^8^ and by 72 percent of male nursing home residents. ^32^ The fraction of nursing home admissions attributable to UI in the elderly population was 10 percent for men and 6 percent for women. ^517^

The prevalence of FI ranges from 0.8 to 5 percent in men and 2 to 6 percent in women living in the community ^518^ and to more than 50 percent in nursing home residents. Indeed, FI is among the most common reasons for nursing home admission. ^21^ The prevalence of combined UI and FI in adults in LTC facilities varied from 4 percent ^519^ to 44 percent. ^34^

Population-based studies underestimate the incidence of incontinence due to sampling and self selection of the survey participants. ^20^ Clinic-based studies included patients actively seeking treatment for incontinence, who represent only a small proportion of incontinent adults. ^13,^ ^19,^ ^146,^ ^520^ Only 45 percent of women and 22 percent of men with weekly incontinence episodes ever sought medical care for UI. Primary care providers diagnosed UI in 21 percent of older incontinent women and in 10 percent of older incontinent men. ^521^ Despite the tremendous impact on quality of life, less than 50 percent of older adults with FI ever asked for professional help. ^17,^ ^522^ – ^524^

Strategies to detect persons at risk and individuals with incontinence have been systematically reviewed for UI ^15,^ ^16^ but not for FI, with no special attention to high-risk populations in either group. Comparative predictive likelihood ratios of diagnostic tests for community dwelling adults and residents in long-term care (LTC) facilities are not well established. ^20,^ ^21^ No systematic reviews addressed the positive likelihood of diagnostic procedures for FI. ^13^

Clinical interventions to reduce UI have been extensively reviewed during the last years by the Cochrane Group, ^492^ – ^495,^ ^525^ – ^548^ and FI ^497^ – ^500,^ ^549^ – ^557^ the International Continence Society, ^20,^ ^21^ the American College of Gastroenterology Practice Parameters Committee, ^17^ and the Agency for Healthcare Research and Quality. ^25,^ ^26^ The basis for measuring successful treatment varied across the studies that examined different interventions; the criteria for deeming a treatment successful are not well established. Pooled analyses of the selected outcomes included small samples of the studies and showed substantial heterogeneity across interventions. Patients and clinicians need synthesized analysis of clinical efficacy and comparative effectiveness of diagnostic and treatment options to make informed decisions of effective care. Policymakers require evidence-based estimations attributable to effective treatment events in different clinical settings and for subgroups of patients.

The cost of incontinence care in the United States increased over the past decades; ^558^ in 2004 it averaged $19.5 billion annually. ^559^ One estimate places the 2000 annualized cost of nursing home admissions due to incontinence at $6.0 billion ($3.0 billion each for elderly men and women). ^517^ Evidence-based recommendations to reduce the risk of incontinence in LTC facilities and in the community could improve health care and the quality of life for incontinent patients.

This review was commissioned as background material for an NIH/OMAR State of the Science Conference on Incontinence. The aims of the present project are: 1) to systematically review published evidence to identify individuals at risk and patients with undiagnosed UI and FI in the community and in LTC settings and 2) to synthesize evidence of the effectiveness of different clinical interventions to prevent the occurrence and progression of UI and FI in adults.

The following questions were developed for this review:

1 What are the prevalence and incidence of urinary and fecal incontinence in the community and long-term care settings?
  - Race
  - Ethnicity
  - Gender
2 What are the independent contributions of risk factors for urinary and fecal incontinence, including:
  - Age
  - Functional impairment
  - Institutionalization
  - Parity, childbirth, and postpartum state
  - Menopause
  - Dietary factors
  - Smoking
  - Obesity
  - Genetic factors
  - Prostate disorders
  - Dementia
  - Psychiatric disorders, specifically depression
  - Diabetes
  - Urinary tract infection
  - Chronic gastrointestinal (GI) conditions such as irritable bowel syndrome (IBS), diarrhea, constipation, and inflammatory bowel diseases (IBD)
  - Cardiovascular and pulmonary conditions
  - Gastrointestinal, gynecologic, and urological procedures
  - Neurological disorders, such as stroke and spinal cord problems
3 What is the evidence to support specific clinical interventions to reduce the risk of urinary and fecal incontinence?
4 What are the strategies to improve the identification of persons at risk and patients who have urinary and fecal incontinence?
5 What are the research priorities for identifying effective strategies to reduce the burden of illness in these conditions?

The analytical framework for Question 2 focuses on risk factors of incontinence in adults (definitions are included in Appendix A). These risk factors can be combined in one person. Independent contributions of isolated risk can be addressed in studies with adequate multivariate analysis. Such population-based studies are available for some risk factors, including age and age-related conditions and behavioral risk factors, but not for surgical procedures and rare diseases. Given this reality, the present systematic review addressed the adjusted relative risk of incontinence in adults with different levels of risk factors when possible and the absolute risk of incontinence in populations after surgical procedures and with specific diseases.

The analytical framework for the strategies to identify patients who have UI and FI included examination of diagnostic values of different tests compared to multichannel urodynamics as a “gold standard” for UI and physician diagnosis for FI. Sensitivity, specificity, positive predictive values, predictive likelihood ratio, and cost effectiveness of the index tests were compared to standard tests. The validity and reliability of incontinence-specific scales were analyzed from published literature. Conceptual and operational definitions of incontinence and risk factors of incontinence are presented in the analytical framework.

To facilitate the discussion of fecal incontinence, we have adopted the practice of using that term to encompass both fecal and anal incontinence. These two terms are frequently used interchangeably in the literature and create a great deal of confusion.