# Appendix F. Evidence Tables

Table F1-a Incidence of urinary incontinence in adults

Author Sample | Subject Selection, Response Rate, Data Source, Measurement Methods (survey, screening, case finding, definition) | Subject Age, Gender, Race, Ethnicity, Residency | | | | Incidence (new cases/year * 100,000 age standardized adult population, males and females) of UI, Overall: by Type, Severity, and Impact on Life
Townsend, 2007 ^1^ | Female nurses selected using data from the Nurses Health Study II which is updated biennially. | Age: 37–54 (Mean: 46.1) | | | | Incident incontinence:
Prospective cohort | Response rate: Approximately 88% | Gender: Female | | | | (2 years) | 13.60%
Adjusted by: Age, BMI, Weight, Race | Data source: Self-reported mailed questionnaires. | Race: Not reported
Parity, Smoking, Oral contraceptive use, Menopausal status, Hormone use, Hysterectomy, Diabetes, Physical activity, | Incontinence was defined as, “Leaked or lost control of urine in the last 12 months.” | Ethnicity: Not reported
Diuretic use | | Residency: USA
Level of evidence: II-2A
Altman, 2006 ^2^ | 304 primiparous women who had a vaginal delivery over a 10-week period in 1995 and completed a bladder function questionnaire | Swedish women with mean age at index delivery 29.9 ± 4.1 years | | | | Adjusted for age and parity, odds ratios for SUI compared with index delivery:
Prospective, observational cohort study with 10-year followup | Excluded: Elective or acute cesarean delivery; inadequate knowledge of Swedish language; dual pregnancy | | | | | - 6 months: RR 2.2, 95% CI: 0.9–5.8; - 9 months: RR 1.8, 95% CI: 1.6–5.4; - 5 years: RR 4.1, 95% CI: 3.1–9.2; - 10 years: RR 3.9, 95% CI: 1.1–8.2
Adjusted for maternal age and parity | [underlined: UI Measurement]: Survey using selfadministered questionnaire | | | | | Adjusted by maternal age and parity, the RR of moderatesevere SUI after first delivery was 5.8, 95% CI 1.2–33.7
Level of evidence: 11–2A | - Do you experience sudden desires to void urine that are difficult to hold back?; - Do you experience involuntary loss of urine at physical activities? | | | | | Mean incidence rates 10-year period before and after index delivery, respectively: # of cases per 1,000 person years
| UI Severity Definition | | | | | - Mild SUI: 5 vs. 30; - Moderate-severe SUI: 2 vs. 10
| - Mild SUI defined as <1/week Moderate-severe SUI defined as UI >1/week or daily
Edwards, 2006 ^3^ | 361/460 patients (78.5% response rate) consecutively admitted with ischemic stroke hospitalized between 1999-2000 | Adults ages 22–90 years with a mean age 65,5 (SD 15.2), USA (Missouri) | | | | - UI group was older (P <.001); - UI more common in women than men (P <.003); - Individuals continent at 6 month followup were functioning significantly better than incontinent stroke survivors; more independent in basic self-care, functional communication, and cognition as measured by FIM (P <.0001); - Individuals continent at 6 months had greater independent in ADLs measured by the FAM (P <.0001)
Prospective cohort study | Inclusion criteria: community residence, absence of serious cognitive or language deficits, no prestroke UI, and met ICD-9 criteria for ischemic stroke | Age: | | | | SF-12 scores
Level of analysis: II-2A | Telephone interview 6 months poststroke | - Continent: 64.6 (SD 15.2) (n=301); - Incontinent: 70.1 (SD (14.8) (n=59) | | | | - Continent vs. Incontinent; - Physical health: 45.6 (SD 6.7) vs. 42.0 (SD 5.4) (P = .18); - Mental health: 43.9 (SD 7.8) vs. (37.1 (SD 6.9) ( P = .0001)
| [underlined: UI Measurement]: Classified as incontinent if FIM bladder management item ≤5 (e.g., experience loss of bladder control at least 1x/month) | Gender:
| | - 160 (47%) male; 137 (46%) continent and 23 (40%) incontinent; - 201 (53%) female; 165 (54%) continent and 35 (60%) incontinent
| | Race:
| | - 181 (50%) white; - 79 (50%) African-American
Engh, 2006 ^4^ | 835/1,022 women (81.7% response rate) ages 40–52 years who underwent uterine surgery with ovaries preserved between 1997-2002 | Women with mean age 44.9 years, Sweden | | | | De novo UI by type of surgery at least 2 years postop:
Case-control | Excluded: preoperative urinary symptoms; 6 or more vaginal deliveries, followup time <2 years, uterine size >9 weeks or uterine weight >120g, previous UI surgery and/or concomitant prolapse surgery | | | | | - Total abdominal/laproscopic hysterectomy; - 236 (75.2%) no symptoms; - 43 (13.7%) SUI; - 10 (3.2%) UUI; - Subtotal abdominal/laproscopic hysterectomy; - 186 (74.7%) no symptoms; - 36 (14.5%) SUI; - 12 (4.8%) UUI; - Total vaginal/laproscopically assisted; - 210 (77.2%) no symptoms; - 39 (14.3%) SUI; - 11 (4.0%) UUI; - Endometrial destruction (control); - 138 (73.8%) no symptoms; - 26 (13.9%) SUI; - 7 (3.7%) UUI; - No significant differences noted between groups
Not adjusted | Types of surgery, n
Level of evidence: II-2A | - Total hysterectomy (abdominal/laproscopic) n=198/116; - Subtotal hysterectomy (abdominal/laproscopic) n=163/86; - Total hysterectomy (vaginal/laproscopic assisted vaginal) n=265/7
| Control group: women undergoing endometrial destruction (ablation, balloon treatment) n=187
| Questionnaire
Glazener, 2006 ^5^ | 3,405/4,537 (75.1% response rate) of women responding they had singleton births delivered over 1 year between 1994-1995 (3489/4555 responded to survey) | Women mean age 26.7 years (SD 5.3), Scotland, New Zealand, and England | | | | UI onset during index pregnancy: 3% (n=101)
Cross-sectional | Excluded: Twin pregnancies Conducted in 3 countries Mailed survey | | | | | UI onset after 3 months index pregnancy: 15% (n=503)
Adjusted | [underlined: UI Measurement]: A positive response to one or more of the following questions:
Level of evidence: | - At present, do you ever lose any urine when you don't mean to?; - In the last month, how often has this happened on average?; - Do you wear a pad for this?
McGrother, 2006 ^6^ | 12,570/19,241 (65.3% response rate) community-dwelling women drawn from 108 general practices (71% of all practices) | Women aged ≥40 years (range 40–98), UK | | | | Incident rate at 1-year: 3.6% SUI
Prospective cohort study with 1-year followup | Mailed questionnaire at baseline and 1 year | Median age: 58 and 56 years
Adjusted for age and ADL; separate models adjusted for general and specific morbidities and parity | [underlined: UI Measurement]: SUI: leakage upon laughing, coughing, or exercise ≥monthly
Level of evidence: 11–2A | Included OAB but could not differentiate those with OAB with urge incontinence from those with OAB without urge incontinence
van Brummen, 2006 ^7^ | Consecutive recruitment of nulliparous pregnant women with single, low-risk pregnancy between 12 and 18 weeks gestation recruited from 10 midwifery practices from January 2002 to July 2003 | Women with a mean age of 30.4 (SF 0.19); Netherlands | | | | Bothersome SUI::
Prospective cohort study | Exclusion criteria: previous urogynaecological surgery, urogynaecological malformations, diabetes mellitus, or neurological disorders; good knowledge of Dutch language; pregnancy within 1 year after index pregnancy | | | | | - 53 (15.4%) at 36 weeks; - 36 (10.5%) at 1 year after childbirth
No adjustment for confounding factors | 344/954 of those invited and not pregnant with 1 year postpartum (37.1% response rate) 344/904 of those eligible (38.1% response rate) | | | | | Moderately or greatly bothersome UUI:
Level of evidence: II-2A | Self-report questionnaire at 12, 24, and 36 weeks gestation, and 3 and 12 months after delivery | | | | | - 58 (16.9%) at 36 weeks; - 51 (14.8%) at 1 year after childbirth
Note: van Brummen, 2006 ^8^ had similar sample but recruited from fewer midwifery practices over same time period | [underlined: UI Measurement:] Using questions from the UDI,
| - SUI was defined as: Do you experience urine leakage related to physical activity, coughing, or sneezing?; - UUI: Do you experience urine leakage related to the feeling of urgency?
| Defined symptom bother using item levels and total scores from UDI
| Baseline continence status unknown
Wehrberger, 2006 ^9^ | 441/925 women (47.7% response rate) who completed a free examination in 1998 or 1999 | Women ages 20–84 years; Austrian | | | | Study described as incidence but unclear how they calculated numbers (see prevalence table)
Prospective cohort study with mean duration of follow-up of 6.5 years | Mailed questionnaire | | | | | Cumulative incidence of any UI over 6.5 years:
Adjusted for confounding factors | [underlined: UI Measurement]: BFLUTS: Have you leaked any urine at all during past 4 weeks? | | | | | - 3.9% annually; - 25.6%
Level of evidence: II-2A | | | | | | By age and frequency, cumulative incidence over 6.5 years (n, n with UI, cumulative incidence, annual incidence??, frequency ≥1 time/week, cumulative, annual):
| | | | | | - 20–39 years: 8/54 (14.8%, 2.3%), frequency = 2 (3.7%, 0.6%); - 40–49 years: 18/70, 25.7%, 4.0%; frequency = 10 (14.2%, 2.2%); - 50–59 years: 22/92, 23.6%, 3.6%, frequency = 10, 10.8%, 1.7%); - 60–69 years, 11/46, 23.9%, 3.7%; frequency = 7, 15.2%, 2.3%; - 70+ years: 18/38, 47.3%, 7.3%, frequency = 13, 24.2%, 5.3%; - Total = 77/300, 25.6%, 3.9%; frequency = 42, 13.9%, 2.1%
| | | | | | Frequency of UI:
| | | | | | - ≤1 time/week: 44%; - 2–3 times/week: 28%; - 1 time/day: 15%; - More often: 13%
| | | | | | UI severity:
| | | | | | - Enough to make underwear/pads damp: 72%; - Enough to make underwear/pads wet: 20%; - Enough to wet outer clothes: 5%; - Urine runs down legs onto floor: 3%
| | | | | | Impact of UI:
| | | | | | - 14% not at all; - 40% a little; - 29% moderate; - 17% significant
| | | | | | UI type:
| | | | | | - 34% SUI; - 13% UUI; - 53% MUI
Andersson,2004 ^10^ | 3/2000, Life and Health questionnaire sent to 70,000 residents randomly selected. In Orebro, pop of 274,000, one of the five counties that participated in above study, a special section on UI was given to a sample of 15,360 residents | 7680 females | | | | Only prevalence rates given — see other table
Population based study | Questionnaire mailed to home comprising 12 questions on UI as a supplement to a large public health survey on health and general living Sample of 15,360 residents aged 18–79yrs of Orebro, Sweden; Response rate was 64.5% | 7680 males
II-3 | Used defs from ICS | age categories
| Stats on wts and calibration and found results were the same | 18–34 | 53.90%
| | 35–49 | 60.3
| | 50–64 | 69.6
| | 65–79 | 72.2
| | Swedish population
Bogner, 2004 ^11^ | Used ECA (Epi Catchment Area) program sample to select from 3,481 community dwelling adults who were initially living in East Baltimore in 1981. | Mean age: 67.2
Population based longitudinal survey | 1,920 were contacted (73% of original cohort). Study sample included 822 persons ≥50 years, who completed info on UI. After exclusions for missing data, the final sample was 747. | 64% were women
II-2B | Age ≥65 over sampled | 72.3% White — mean age 68.2±11
| GHQ used and self report on UI. UI = “Have you ever had any difficulty in controlling your water, losing your urine or having trouble getting to the bathroom on time?” If any uncontrolled urine loss was reported within the 12mos before the interview, persons were classified as having UI. | 27.7% AA — mean age 64.5±10
| | | White | AA
| | diabetes | 14.3 | 16.9
| | heart trouble | 27.4 | 26.6
| | arthritis | 51.1 | 56.5
| | stroke | 8.2 | 7.3
| | cancer | 14.4 | 6.3
| | MME | 27.6+-2.6 | 25.6+-3.6
| | ADL impaired | 1.9% | 3.9%
| | (AA and Whites ≥50years at followup interview 1993-1996)
Corcos, 2004 ^12^ | Population ≥35 years, stratified by census of metro area and by gender. | 48.2% men; mean age=52
Prospective cohort | 7,487 persons were sample base. | 51.8% women; mean age=50.9
No control mentioned | 53.7% response rate. 3249 interviews were final sample. Investigators developed standardized questionnaire to ascertain OAB and SUI and impact on QoL. | 82.4% younger than 65 and 17.6% older Montreal, Toronto, Vancouver and Edmonton, Canada
| Computer assisted telephone interviews conducted in 2 steps: an initial questionnaire to evaluate presence of OAB followed by detailed questionnaire to complete assessment.
Dallosso,2004 ^13^ | Part of the Leicestershire MRC Incontinence Study. This study focused on women living in the community in UK age ≥40. Of a random sample of 20,244 women drawn, 12,565 returned the questionnaire (65% response rate). | Baseline data compared to those who provided FFQ data - | | | | Incidence rate over 1 yr of f/u was 8.3%
Prospective longitudinal study | FFQ sent to 10,852 of above sample, 1^st^ Postal questionnaire mailed Oct 1998 and completed by 7,046 women(response rate 65%). 2^nd^ postal questionnaire mailed Oct 1999 and completed by 6,424 women (91% response rate). | Median age 57 vs. 61 | | | | Highest in perimenopausal group (40–49) and in the very elderly (80+)
II=2B | Excluded women living in residential or nursing homes and those of South Asian origin who make up 5.3% of Leicestershire pop > 40years. | Rating of health poorer in baseline after adjusting for age (OR: 1.66; 95% CI 1.51–1.82) | | | | | Incidence at 1 year followup
| Used ICS definitions | More long term health problems in baseline (OR 1.14; 95% CI, 1.05–1.25) | | | | | Total N | SUI cases %
| | No difference in reporting SUI (OR: 1.02; CI 95%, .92–1.13) | | | | 40–49 | 1,242 | 9.3
| | | | | | 50–59 | 1,272 | 7.2
| | | | | | 60–69 | 1,108 | 7.6
| | | | | | 70–79 | 756 | 8.3
| | | | | | 80+ | 214 | 12.6
Dallosso, 2003 ^14^ | 7,046 women at baseline with follow up collected from 6,426 1 year later, age ≥40 living at home, part of the Leicestershire MRC Incontinence Study on prevalence and incidence including men and women begun 10/98 with followup in 10/99 | Age | | | | Prevalence of OAB increased with age but no marked change with SI
Longitudinal, Prospective cohort | Postal survey with usual definitions of SI. OAB defined by ICS and for this study as one or both of the sxs urge leakage and urgency. Subgroups of OAB and SI | 40–49 | - 26% | | | 1 yr f/u there were 492 new cases of OAB and 421 cases of SI giving incidence rates of 9.2% and 8.3% respectively
II - 2B | Excluded nursing home or residential pts and SI at baseline was excluded from analysis of onset of S.( 19,239 eligible women; 65.3% returned N= 12,565, 6,426 in this study) | 50–59 | 27.4% | | | Being overwt or obese were both sig associated with an increased risk of SUI (OR: 1.42; 95% CI, 1.09–1.84 and OR 1.91; 95% CI, 1.38–2.63) respectivelly
| | 60–69 | 23.3%
| | 70–79 | 17.1%
| | >80 | 6.2%
| | BMI
| | Acceptable | 48.4%
| | Underwt | 7%
| | Overwt | 31.4%
| | Obese | 13.3%
| | Smoking
| | Never | 54.3
| | Exsmoker | 30.3
| | Current | 15.2
| | United Kingdom
Deliveliotis, 2004 ^15^ | 283 of 441 pts enrolled; 105/142pts tx with RRP for prostate cancer, 98/151pts tx with TURP for BPH, 80/148 healthy men as control completed surveys | Greek men | | | | | RRP | | TURP
Prospective cohort | Used AUA Sx Index, UCLA Prostate Cancer Index; Rand 36-Item Health Survey and BMSFI translated into Greek | Mean ages | | | | Pretx | post | p | pretx | post | p
II-2A | Patient outcomes 2 years post tx compared to pretx status at 2 weeks prior to tx | 67.4 | range 55–75 | | group 1 | Urinary function
| Investigators felt poor returns due to length of questionnaires and the number of them | 70.3 | range 58–74 | | group 2 | 85.1 | 80.2 | .121 | 71.2 | 87.3 | .005
| | 72.4 | range 62–82 | | control | Urinary Bother
| | HRQOL post tx RRP | | | | 85.1 | 70.6 | .021 | 65.1 | 80.2 | .003
| | TURP Control | | | | AUA SI
| | Physical functioning 81.5 78.1 82.3 | | | | 11.1 | 8.6 | .812 | 24.2 | 8.2 | .001
| | | | | | UI every day
| | | | | | 2% | 9% | .002 | 12% | 2.78% | .002
| | | | | | RRP had trend towards worse urinary function 2yrs after surgery but diff not significant. Urinary bother deteriorated.
| | | | | | UI in control group was 5.78%
Grodstein, 2004 ^16^ | Nurse Health Study from 1996-2000 females, Cohort of 39,436 women 50–75 years | Mean age; 61 for current HRT use; 64 for never used. BMI for never used HRT was 27, current use BMI = 47, past BMI = 47. | | | | 5,060 incident cases of occasional UI and 2,495 incident cases of frequent UI
Prospective cohort | Questionnaire mailed in 1996 to 39,436 post menopausal women who had no leaking of urine and were followed for 4 years | Smokers @45% all. | | | | Average incidence rate of 3.2% per year and 1.6% per year respectively
II-2A | Incident cases of occasion UI defined as leaking 1–3 times/month; frequent ≥1/week | HRT use:
Confounded for stroke and physical limitations and results were the same in both analysis | Excluded premenopausal women or users of estrogen creams, or reported leaking in 1996 | | Never | Current | Past
| | Cauc | 98 | 97 | 98
| | AfrA | 1 | 1 | 1
| | Hisp | 0 | 1 | 0
| | Asian | 1 | 1 | 1
| | Hysterectomy
| | | 16 | 47 | 40
Hagglund, 2004 ^17^ | 145 incontinent and 193 continent women 22–50 years in 2000 follow up, who participated in 1995 study on prevalence. | Sweden | | | | At 4 year followup in 2000 118 women were found to be incontinent. Of these, 95/118 had remained incontinent.
4 year followup cohort study | Response rate 73% 248/338 | | | | | 130 women were continent. Of these women, 112/130 had remained continent.
II-2A | Among the 248 responders as followup, 118 reported UI and 130 reported being continent. | | | | | Incidence rate from 1996-2000 was 17% (23/135) with a mean annual incidence rate of 4%
| Changes in type of UI measured using DIS “do you have problem with involuntary loss of urine?” | | | | | Persistence of UI — this group consisted of 95 women. 28% reported UI daily, 34% reported UI weekly, 16% reported monthly and 22% reported seldom.
Haltbakk, 2004 ^18^ | 480 Norwegian men at St. Olavs Hospital, Trondheim Norway. Tentative dx of BPH made on 612 patients and from this pool, sample analyzed was 480 (78%). | Mean age of patients was 67 years, SD 10.6 years; median 69 years range 39–91 years
Prospective cohort no control mentioned historical control | ICS LUTS questionnaire (ICS-BPH) between 1997-2000. IPSS, SPI and SISI used also. | 15% mild sxs
| UI defined as any involuntary leakage of urine. | 54% moderate sxs
| | 31% severe sxs
| | mean age in incontinent group was 68 years
Holroyd-Leduc, 2004 ^19^ | 6,506 of 7,447 subjects ≥70 in the Asset and Health Dynamics Among the Oldest Old study who had complete info on continence status at baseline. 3 groups- 5,872 nursing home, 5,521 ADL decline and 5,509 IADL decline as outcomes | Mean age =/- SD = 77 (range 69–103)
Population based | Subjects interviewed in 1993 and 1995 | 63% female
Prospective cohort | Blacks, Hispanics and Florida residents were over sampled | 86% white
Confounders — sex, age, sex, race, smoking, alcohol, BMI, sensory impairment, comorbid disease, depression, cognitive function and baseline dependency. | Overall response rate was 80% | Median number of baseline comorbid medical conditions was 2
II-2A | UI measured “next question might not be easy to talk about, but it is very impt for research on health and aging, during the last 12 mos, have you lost any amount of urine beyond your control?” | 10% received help ≥1 ADLs;
| | 23% were receiving help in ≥1 IADLS at baseline
| | Patients with UI had more comorbidities (p=.001), higher rate of visual impairment (35% vs. 22.4% p <.001) and hearing impairment (39.7% vs. 30.5% p<.001)
| | More functionally impaired at baseline
| | Community dwelling in US
Hunskaar, 2004 ^20^ | Postal survey mailed to 29,500 households in 4 countries — France, Germany, UK and Spain age >/= 18yrs 58.1% response rate. Women with UI included in analysis = 5,976 (35% of study pop) | Mean age
Cross national study, Prospective | Definitions used by ICS; sxs in last 30 days and in last 7 days | France — 44.8
No control group | | Germany — 59
| | UK — 45
| | Spain — 64
| | All — 58
Jackson, 2004 ^21^ | 1,584 white and black women 70–79 years at 2 clinical sites in Pittsburg and Memphis. 1,558 answered the questions | Smoking
Cross sectional analysis, longitudinal study | Limited enrollment to those who reported no difficulty walking quarter mile, climbing 10 steps or performing ADLs | Alcohol
II-2A | Questionnaires — in the past 12 mos, have you leaked even a small amt of urine? How often have you leaked? | Depression
| | Diabetes
| | BMI
| | Parity
| | Hysterectomy
| | Oral estrogen use
| | COPD
| | Stroke
| | Arthritis
| | Age
| | Race
Jackson, 2004 ^22^ | 1,017 post menopausal US women a 55–75 years enrolled in HMO and followed for 2 years (1998-2002) inclusion criteria were no natural menstrual cycle in past 12 months (oral estrogen or vaginal estrogen users were excluded), resided in Washington state. Exclusion factors were residential nursing care, restriction to wheel chair, dementia or severe psych disorder, indwelling catheter or intermittent urinary catheter, end stage renal disease requiring dialysis, active malignancy other than skin cancer and chronic antibiotic use. Acute cystitis in past 90 days exclusionary. | Risk factor (%) Crude HR (95% CI) | | | | Incidence of UTI was .07 per person per year.
population based | Postvoid residual bladder volume measured using portable ultrasound device. | Complete sample 1,017 | | | | Independent predictors of infection included insulin treated diabetes (hazard ratio [HR]=3.4;95%confidence interval [CI]: 1.7 to 7.0) and a lifetime history of urinary tract infection(HR for six or more infections = 6.9; 95% CI: 3.5 to 13.6). Borderline associations included a history of vaginal estrogen cream use in the last month (HR = 1.8; 95% CI: 1.0 to 3.4), a history of kidney stones (HR=1.9; 95% CI: 1.0 to 3.7), and asymptomatic bacteriuria at baseline (HR= 1.8; 95% CI: 0.9 to 3.5).
Prospective cohort; also randomly selected from HMO diabetes registry | 12 month f/u done by 87% and 24mo f/u by 81%. | Age (years)
II-2A | Primary study outcome was sx cystitis | 55–59-32% | 1.0
| | 60–69- 42% | 1.3 | (0.8–2.2)
| | 70–75- 26% | 1.6 | (0.9–2.9)
| | Ethnicity
| | White- 87% | 1.0
| | Other-12 % | 0.6 | (0.3–1.2)
| | General health score from SF-36
| | 76–100(51%) | 1.0
| | 51–75(37%) | 2.0 | (1.2–3.3)
| | 0–50 (12%) | 2.6 | (1.3–4.8)
| | Smoking history
| | Never (55%) | 1.0
| | Former (39%) | 0.9 | (0.5–1.4)
| | Current (6%) | 0.1 | (0.02–0.8)
| | Diabetes at baseline
| | No (79%) | 1.0
| | Yes (21%) | 1.9 | (1.1–3.1)
| | Diabetes treatment type
| | Not diabetic (79%) | 1.0
| | Diet/pill (17%) | 1.2 | (0.7–2.0)
| | Insulin (4%) | 4.7 | (2.2–10.3)
| | Accidental leakage of urine in last year
| | No (34%) | 1.0
| | Yes (66%) | 1.6 | (0.9–2.7)
| | Type of urinary incontinence in last month
| | None | 1.0
| | Stress only | 0.9 | (0.5–1.8)
| | Urge only | 1.7 | (0.8–3.6)
| | Mixed | 1.4 | (0.9–2.4)
| | Postvoid residual bladder volume, ml
| | <50ml (79%) | 1.0
| | 50–100ml (10%) | 1.1 | (0.5–2.2)
| | >100ml (10%) | 1.6 | (0.8–3.2)
| | History of hysterectomy
| | No (69%) | 1.0
| | Yes (31%) | 1.2 | (0.8–2.0)
| | History of kidney stones
| | No (90%) | 11.0
| | Yes (5%) | 2.4 | (1.2–4.9)
| | History of bladder or urinary surgery
| | No (90%) | 1.0
| | Yes (10%) | 1.6 | (0.9–3.0)
| | Parity (N of full-term pregnancies)
| | 0-(14%) | 1.0
| | 1–3-(63%) | 1.3 | (0.7–2.5)
| | >4-(23%) | 2.2 | (1.1–4.3)
Johnson, 2004 ^23^ | Men from the Prostate Cancer | 1,433 men RRP | | | | Wt % for men with RRP
Long term cohort, Prospective study of RRP vs. Radiotherapy | Outcomes Study dx with primary prostate cancer between Oct 1994–Oct 1995 | 642 men received radiotherapy | | | | | NHW | AA | Hispanic
II-2B | Residents of LA, King County Washington, states of CT, NM, U,T 60–89 years in King County and younger >90 in others. | RRP group — wt % by race | | | | Level of urinary control baseline
| Self questionnaire at 6, 12, 24 and 60 mos after diagnosis and medical record review at 12 and 60 mos. | | NHW | AA | Hisp | Total control | 87.9 | 86.6 | 80.5
| 11,137 men identified in registries; 5,672 randomly selected, letters sent to 4,736(83.5%) of selected cases. Total of 3,533 men(62.3%) completed 6 and 12mo were included in f/u cohort. | Arthritis: | 33.3 | 38.6 | 35.8 | Occ leakage | 8.8 | 9.5 | 11.2
| 1433 men had RRP completed 6mos | Diabetes: | 11.1 | 29.5 | 17.2 | Freq leakage | 2.1 | 2 | 6.5
| 1178 did 24 mos (82.2%) | COPD: | 7.5 | 6.6 | 5.4 | P = | | .77 | .29
| 1109 did 60mos (77.4%) | HF: | 4.9 | 2.1 | 4.4 | 6 months
| For Radiotherapy — urinary problems not reported | CVA: | 2.6 | 2.5 | 3.3 | total control | 22.7 | 27.6 | 28.9
| Questionnaire also translated into Spanish and interview conducted in Spanish when necessary. | HTN: | 37.3 | 54 | 37.5 | occ leakage | 52.1 | 44.2 | 40.8
| | MI: | 7.9 | 4 | 4.2 | freq | 22.6 | 23.4 | 26.7
| | Age at dx | | | | p = | | .57 | .83
| | <60 | 27.5 | 38.6 | 23.4 | 12 months
| | 60–64 | 26.8 | 26.1 | 30 | total control | 33.1 | 38.5 | 37
| | 65–75 | 41.9 | 32.9 | 45.5 | occ leakage | 50.2 | 51.4 | 46.9
| | ≥75 | 3.8 | 2.4 | 1 | freq | 15.6 | 9 | 14.9
| | | | | | p= | | .24 | .26
| | | | | | 24 months
| | | | | | total control | 38.2 | 41.9 | 35.2
| | | | | | occ leakage | 50.2 | 45.1 | 53
| | | | | | freq | 9.8 | 11.1 | 11.3
| | | | | | p = | | .86 | .38
| | | | | | 60 months
| | | | | | total control | 30.8 | 49.3 | 32.8
| | | | | | occ leakage | 53.7 | 39.7 | 47.4
| | | | | | freq | 14.3 | 10.4 | 18.7
| | | | | | p = | | .01 | .36
| | | | | | *definitions of occasional and frequent were not given
Lagergren, 2004 ^24^ | 65–79years old = 12%, >80years = 6% | Men 3,052
National, longitudinal, multipurpose study in Sweden (SNAC). Study consisted of two parts — population part and the care/service part. | Of a total pop of 17,044, 8,627 ≥65 years were targeted and 7,518 sampled from 2001–March 2004. | Women 4,465
II-2A | 16–25% of SNAC received public care | Total 7,518
| F/u every 6 years starting at age 66 | Avg age 85 compared to national avg age 83 Skane, Karlskrona, Kungshomen and Nordanstig, Sweden
| Combo of interviews and questionnaires
Liebling, 2004 ^25^ | 393 UK women with term singleton, cephalic pregnancies who required op delivery at full dilatation between 2/1999–2/2000 from a cohort of 10,106 deliveries | Instrumental C-section OR (95% CI) | | | | Incidence of urinary sxs (at least occasional episodes of UI) after delivery was reported by 43% and 22% in each group, respectively, at 6 weeks and 52% and 32% at 1 year.
Prospective study | Postal questionnaires at 6wks and 1yr study conducted at St. Michael's Hospital, Bristol, UK | | (184) | (209) | | 6 weeks | | | 1 year
| Only instrumental vaginal deliveries performed in surgery as the definition of difficult vaginal operative delivery. | Primi | 78% | 79% | 1.09(.67–1.77) | | Instr. delivery | c-section | inst. delivery | c-section
| | Age>35 | 14% | 9% | | UI | 16.2% | 2.7% | 17% | 5.4%
| | Nonwhite | 7% | 5% | | OR | 7.8 (2.58–23.55) | | OR 3.12 | (1.27–7.64)
| | BMI>30 | 7% | 15% | .44(.22–.86) | Difficulty holding on to urine
| | 25% attempted with forceps | | | | | 9.6% | 2.7% | 12.9% | 6.6%
| | 51% ventouse | | | | OR 3.59 | (1.22–10.54) | | OR 1.90 | (.81–4.45)
| | 24% ventouse and forceps
| | 59% rotational del attempted
McGrother, 2004 ^26^ | 162,533 prevalence study and 39,602 incidence study subjects ≥40 years | 15% age ≥ 65 yrs | | | | Annual incidence rates: 6.3% in men and women combined
Cross sectional and longitudinal | Response rate 60 and 63% respectively and 79% at follow up | 85.5% white | | | | In women: 8.8% overall: 8.4% 40–49 years; 7.9% 50–59 years; 8.5% 60–69 years: 9.4% 70–70 years; 14.7% ≥80 years
II - 2B | Excluded people living in institutional settings | 44.9% employed | | | | In men: 3.8% overall; 2.2% 40–49 years; 2.5% 50–59 years; 4.0% 60–69 years; 7.1% 70–79 years; 10.9% ≥80 years
| Response rate at 1 year: | 91.8% good health | | | | Period prevalence was: moderate or greater incontinence, 16.1%; storage disorder, 28.5%; storage sxs with impact on QoL, 30.4%, healthcare need, 37.1% and requirement 20.4%.
| 79.8% women (n=12,036) | Mean age 57 | | | | Remission rates substantially greater in men than women.
| 77.6% men (n=7,823) | 54% women | | | | Over a year, 20.4% of people aged ≥40 yrs, have requirement in terms of seeking or desiring help or wanting more help for storage sxs.
| [underlined: UI Measurement]: Daytime or evening urine leakage | U.K. | | | | In men: 3.8% overall; 2.2% 40–49 years; 2.5% 50–59 years; 4.0% 60–609 years; 7.1% 70–79 years; 10.9% ≥80 years
| Almost dry: minimal | | | | | Weekly wetting prevalence was 2.5 times higher in residential care than in the community.
| Damp: moderate | | | | | Women: | Men:
| Wet: severe | | | | | Overall:
| Profound: soaked | | | | | 5.5% minimal | 5.5% minimal
| | | | | | 3.9% moderate | 3.9% moderate
| | | | | | 4.0% severe | 4.0% severe
| | | | | | 0.8% profound | 0.8% profound
| | | | | | Minimal leakage:
| | | | | | 13.3% 40–49 years | 3.5% 40–49 years
| | | | | | 13.5% 50–59 years | 5.0% 50–59 years
| | | | | | 11.1% 60–69 years | 6.6% 60–69 years
| | | | | | 8.6% 70–79 years | 7.9% 70–79 years
| | | | | | 6.3% ≥80 years | 7.0% ≥80 years
| | | | | | Moderate leakage:
| | | | | | 7.7% 40–49 years | 2.0% 40–49 years
| | | | | | 7.9% 50–59 years | 3.1% 50–59 years
| | | | | | 7.0% 60–69 years | 4.7% 60–69 years
| | | | | | 6.4% 70–79 years | 6.4% 70–79 years
| | | | | | 6.8% ≥80 years | 7.9% ≥80 years
| | | | | | Severe leakage:
| | | | | | 9.8% 40–49 years | 1.6% 40–49 years
| | | | | | 11.7% 50–59 years | 2.5% 50–59 years
| | | | | | 12.0% 60–69 years | 4.6% 60–69 years
| | | | | | 13.2% 70–79 years | 7.9% 70–79 years
| | | | | | 17.0% ≥80 years | 12.0% ≥80 years
| | | | | | Profound leakage:
| | | | | | 2.0% 40–49 years | 0.3% 40–49 years
| | | | | | 2.9% 50–59 years | 0.6% 50–59 years
| | | | | | 3.3% 60–69 years | 0.9% 60–69 years
| | | | | | 4.2% 70–79 years | 1.1% 70–79 years
| | | | | | 9.6% ≥80 years | 3.6% ≥80 years
Neumann, 2004 ^27^ | Study group — 549 women who had hysterectomy during 1/1/98–12/31/2000 born after 1939 | Caucasian | | | | Pre urinary sxs in relation to mode of hysterectomy:
Prospective study | Background group — 144 women, born between 1940-1965, who had non-GYN surgery. | Women: | | | | | Supracer | Tot | Abd | Vag Backgd
II-2A | Exclue nulliparae | 12% hysterectomy — 33% of these had abdominal, 55% had vaginal | | | | | 53 | 51 | 247 | 110
| Questionnaire sent 9–45 mos postop | Denmark. | | | | % of N listed
| SI as involuntary leakage during effort, Urge as leakage with a sense of urgency, sig UI was defined as involuntary leakage at least once a week, bothersome UI as sig incontinence and use of devices, decreased social ability or having hygienic problem with incon. | | | | | Sig SI | 17 | 17 | 15 | 18
| Questionnaires returned by 82% in study group, 76% in background group | | | | | Sig Urge | 13 | 3 | 6 | 7
| | | | | | Bothersome SI | 17 | 12 | 9 | 15
| | | | | | Both. urge | 13 | 3 | 5 | 6
| | | | | | | Supracer | Tot | Abd | Vag Backgd
| | | | | | | 53 | 1 | 247 | 110
| | | | | | % of N listed
| | | | | | Sig SI | 36 | 26 | 29 | 28
| | | | | | Sig Urge | 19 | 11 | 14 | 11
| | | | | | Bothersome SI | 28 | 19 | 23 | 22
| | | | | | Both. urge | 11 | 7 | 13 | 9
Østbye, 2004 ^28^ | 8,949 adults aged 65 and over who were participants in the Canadian Study of Health and Aging: | Age at baseline: | | | | Cumulative 5-year incidence:
Population-based with 5 and 10-year follow-up | | Women: | | | | Women:
| | 65–74: 2,159 (40.6%) | | | | 14.3% ages 65–74 years
| | 75–842,254 (42.4%) | | | | 20.5% ages 75–84 years
| | 85+: 909 (11%), | | | | 24.3% ages 85+ years
| | Men: | | | | Men:
| | 65–74: 1,722 (58.9%) | | | | 8.6% ages 65–74 years
| | 75–84: 1,455 (40.2%) | | | | 12.3% ages 75–84 years
| | 85+: 397 (11%) | | | | 23.2% ages 85+ years
| | Race/ethnicity: not reported | | | | Remission at 5 and 10 years:
| | Residence: Canada | | | | 37% and 40% women
| | | | | | 29% and 38% men
Ozerdogan, 2004 ^29^ | 625 women living in Turkey ≥20years from 4 different cities of Turkey | Age distribution
Cross sectional study, Prospective | Questionnaire and I-QOL: | 20–29 — 26.4%
II-2A | Rare — UI less than once a month | 30–39 — 22.6
| Reg — UI more than twice per month | 40–49 — 18.7
| Serious — continuous use of sanitary protection | 50–59 — 13.4
| SI and Urge defined as usual definitions | 60–69 — 11/7
| | ≥70 — 7.2
| | Illiteracy rate 9.4%
| | 1 in 4 resided in rural area
| | 1 in 5 had ≥4 births and most were vaginal deliveries (25%)
| | 50% BMI >25
| | 25% smokers
| | Recurrent UTIs 19%
| | Diabetes 6.6%
| | COPD — 7.5%
| | Neurological disorders 11.2%
Schytt, 2004 ^30^ | After childbirth 5,550 women from 593 clinics booked appts during recruitment time. Of 4,500 eligible, 3,191 consented, 3,061completed 1^st^, 2,762 completed 2^nd^, and 2,563 completed 3^rd^ questionnaire. 2,450 completed all 3 with 2,390 total after exclusion. | Avg gestation answering 1^st^ quest — 16 weeks, 2^nd^ — 10 weeks post, 3^rd^ — 1 year and 2 weeks.
Prospective, longitudinal cohort | Selected data from a National Swedish survey investigating physical and psychological assessment of childbirth (May and Sept 1999 and January 2000 antepartal visits) | Avg age at recruit — 29.5 years
II-2A | 3 questionnaires; 1^st^ at baseline, 2^nd^ mailed 6–8 weeks after the birth and 3^rd^ 1 year after birth. Women were asked to recall any sxs of UI during and post-pregnancy. | Primiparas — 44%
| Excluded miscarriages, non-Swedish speaking, and women at nonparticipating clinics, delivery of twins | Multiparas — 56%
| | 79.2% had vaginal delivery
| | 13.4% had c-section
de Tayrac, 2004 ^31^ | French women — study pop 717 who had Dargent and Rudigoz technique 449 did not respond | | Vaginal hyst. | Control
Case control, retrospective study | 365 (50.9%) returned questionnaires | Age | 51.4 | 50.9
II-3 | 51 excluded leaving 314 women | Parity | 2.1 | 2.2
| 117 pts who had a vaginal hysterectomy for menorrhagia from Jan 1991 to Dec 2001 | Menopause | 43.5% | 47.4%
| control group of 116 pt who had conservative tx | Smoking | 17.9% | 17.2%
| 197 had hyster for pelvic pain and 117 for menorrhagia | Drink >2 L/d | 7.7% | 9.5%
| Self report questionnaire | Hx of uro sxs | 0 | 0
Hu, 2003 ^32^ | Subject selection: 12,079 patients who underwent radical prostatectomy were identified in the claims data of a 5% national random sample of beneficiaries from the CMMS. | Men aged >65 years | | | | The 3-year incontinence rate decreased from 20% in 1991 to 4% in 1995.
Retrospective longitudinal study. | Study done to ascertain whether radical prostatectomy outcomes improved after the diffusion of surgical innovations during the last decade. | USA | | | | On multivariate analysis nonwhite patients were at increased risk for in hospital complications (OR 1.34, 95% CI 1.17 to 1.55)
Level of evidence:
Kolominsky-Rabas, 2003 (7715059) | 752 adults with first-ever stroke and no UI prior to stroke were prospectively identified from the Erlangen Stroke Project. Of these, 586 had information on UI presence prior to stroke (84%) | 55% female | | | | 35.3% UI incidence at day 7
Population-based, longitudinal survey | | 45% male | | | | 28% full incontinence
Adjusted by age, continence status, disability, stroke type, dependency and setting prior to stroke, independence | | Mean age of those without UI at Day 7: 68.1 and those with UI: 74.7) | | | | 7% partial incontinence
| | Race/ethnicity: not identified | | | | 24% UI at 12 months
| | Residence: Bavaria, Germany | | | | 12% full incontinence
| | | | | | 12% partial incontinence
| | | | | | Significant differences between those with UI and without UI at day 7:
| | | | | | Age: 74.7 vs. 68.1 (P =.001)
| | | | | | Age group: < 65 years: 17% vs. 31%; 65–74 years: 25% vs. 36%; 75–84 years: 40% vs. 26%; >85 years: 17% vs. 7% (P =.001)
| | | | | | Female gender: 59% vs. 51%, P=NS
| | | | | | Cerebral infarction: 78% vs. 91%; intracerebral hemorrhage: 8% vs. 20%; subarachnoid hemorrhage 2% vs. 0%; undefined type (no CT scan): 0% vs. 1%; P=.001
| | | | | | Disability at day 7:
| | | | | | Very severe disabled: 80% vs. 1%;
| | | | | | Severe disabled: 8% vs. 9%; Mildly disabled: 8% vs. 16%; moderate disabled: 5% vs. 43%; not disabled: 0% vs. 30%, P =.001
| | | | | | Living situation before stroke:
| | | | | | Independent at home: 67% vs. 88%; dependent at home: 21% vs. 9%; institution: 8% vs. 2%, missing: 4% vs. 2%, P=.001
| | | | | | Comorbidity before stroke:
| | | | | | Diabetes: 29% vs. 23%, P = NS
| | | | | | Hypertension: 62% vs. 63%, P = NS
| | | | | | Cardiac risk factors: 56% vs. 45%, P =.03
Long, 2003 ^33^ | Patients admitted from June 1999 to June 2001 with various indications for hysterectomy were evaluated. 22 patients were postmenopausal and had received hormone replacement therapy. | Women | | | | Incidence of UI Post-op
Prospective/Observational | 54 excluded due to: (i) the presence of peculiar pelvic mass (anterior wall or low-lying uterine myoma >5cm diameter) (n = 10); (ii) conversion to laparotomy (n = 3); (iii) intraoperative bladder rupture (n = 4); (iv) diabetes mellitus type 2 (n = 10); (v) combined colposuspension or TVT procedure (n = 12); and (vi) incomplete medical records (n = 15). | Age: | | | | SUI
II-2 | Data pertaining to 151 women was therefore assessed for this study. | Range 35 to 61 years | | | | Pre-op: 29.1%
| | Mean: 45 years; | | | | Post-op: 15.2
| | Parity ranged from 0 to 6, with a median of 3. | | | | UUI
| | Taiwan | | | | Pre-op: 7.3%
| | | | | | Post-op: 7.9%
Yip, 2003 ^34^ | Subject selection: 276 nulliparous women were asked to participate; recruited consecutively on day 1 postpartum after a singleton, full term, vaginal delivery. Women with history of UI (including ante-partum stress UI), cesarean delivery, multiple pregnancy, or breech delivery were excluded. | Women | | | | Prevalence
Observational (Cohort) | Response rate: 148 (53.6%) women answered a telephone interview. | Age range: 23–30yrs | | | | UI
II-2 | Definition: Urinary stress incontinence was defined as “2 or more episodes of urinary stress incontinence occurring in the past month” | Hong Kong | | | | Women without interval vaginal delivery: 28.6%
| | | | | | Women with one interval vaginal delivery: 21.1%
| | | | | | 25.7% of women suffered from urinary incontinence 2
Kherulff, 2002 ^35^ | Enrolled women 1,299 undergoing hysterectomy for noncancerous conditions from February 1992 to October 1993 at 28 hospitals. (81% response rate) | Women ages ≥18, with a mean age 43.3 years; Maryland, USA | | | | Prior to hysterectomy:
Prospective cohort with 2-year follow-up | Excluded: <18 years, cancer as indication for hysterectomy | 65% white | | | | - 29.5% (n=382) had severe UI; - 35.9% (n=464) had moderate UI; - 34.ˆ% (n=447) had mild or no UI
Adjusted by age, race, income, and hysterectomy indication | Interviews prior, and at 3, 6, 12, 18, and 24 months post-hysterectomy | 32% black | | | | Preoperatively, UI severity global measure (during last month how much of problem was urination?)
Level of evidence: II-2B | UI Measurement: Urinary Symptom Scale for Women (USSW) adapted from questions in the Main Women's Health Study; In the past month how often have you dripped or leaked urine? In the past month how often have you had urine drip when you sneezed or coughed? | 2% other | | | | - 16.4% (n=212) big problem; - 18.9& (n=245) medium problem; - 22.0% (n=285) small problem; - 42.8% (n=555) no problem
| | Maryland Women's Health Study, USA
Viktrup, 2002 ^36^ | Consecutive recruitment of 305 primiparious women attending obstetric department 91.0% response rate of those who were initially contacted at time of delivery, n=278) | Women ages 17–41 years (median 26 years); | | | | 32% had SUI during pregnancy, 6% had daily SUI, and 1% reported social and hygienic discomfort
Prospective cohort with 5-year follow-up | Standard questionnaire sent within 2–5 days after 1st delivery, telephone 3 months later; same questionnaire mailed 5 years later | Denmark | | | | 19% reported SUI during 1^st^ puerperium, 5% daily SUI, 2% social and hygienic discomfort
Adjusted by maternal age, parity, gestational age, length of first stage, length of second stage, birth weight, head circumference, anesthesis, delivery method, perineal lesions, perineal injury | UI Measurement: Asked if they had urinary incontinence; if incontinence was provoked by physical exerting (SUI) or accompanied by strong desire to void (UUI); if they had daily UI; and if UI was a hygienic or social problem (Using ICS definition) | Race not reported | | | | 6% SUI 3 months after 1^st^ delivery, 1.4% daily SU, and 0.3% had social and hygienic discomfort
Level of evidence: II-2A | | | | | | 5 years after first delivery, 30% (83/278) had SUI, 6% (17/278) had daily SUI, and 8% (23/278) complained of hygienic or social discomfort
| | | | | | UUI 5 years after first delivery occurred concomitantly with SUI in 49% of women with SUI during pregnancy and 36% of women with SUI during 3-month puerperal period
Miles 2001 (14687387) | Random sample of 2,660/3,051 Mexican Americans aged 65 years and over who were participants in the Hispanic Established Population for Epidemiologic Studies of the Elderly (HEPESE); 2,025 persons had data at baseline and at the 2-year followup | Mean age at baseline of continent subjects: 71.9 years, and incontinent subjects: 73.6 years | | | | 14.1% with prevalent UI at baseline and 16.1% at 2-year followup:
Population-based, longitudinal survey | Home interviews | 57% women | | | | 11.6% with new UI at 2-year followup
Adjusted by depression, self-reported number of medical conditions, BMI, gender, age, lifetime smoking, ADLs, and IADLs | UI measured by asking subjects how often they experienced difficulty holding urine. If answered “some,” “most” or “all,” categorized as incontinent | Mexican-Americans Texas, New Mexico, Colorado, Arizona, and California | | | | Weighted sample of 436,533 persons, 60,565 had prevalent UI at baseline, and 32, 271 became incontinent at 2-year followup
II-2A | | | | | | Prevalent UI:
| | | | | | ADLs: 1.5 [0.9–2.7]
| | | | | | IADLs: 1.0 [0.7–1.5]
| | | | | | Walking: 1.6 [1.0–2.4]
| | | | | | Balance: 1.0 [0.6–1.6]
| | | | | | Chair rises: 1.1 [0.7–1.6]
| | | | | | Incident UI:
| | | | | | ADLs: 1.3 [0.6–2.6]
| | | | | | IADLs: 1.7 [1.1–2.6]
| | | | | | Walking: 2.0 [1.2–3.0]
| | | | | | Balance: 2.0 [1.2–3.2]
| | | | | | Chair rises: 2.0 [1.3–3.1]
Møller 2000 ^37^ | 2,860 of 4,000 (71.5%) women aged 40–60 years who were originally randomly selected from the Danish Civil Registration System; After 1-year 2,284 (79.9%) completed 1-year follow-up study | 21.9% age 40 | | | | Incidence at 1-year:
Population-based with 1-year followup | Mailed questionnaire | 20.7% aged 45 | | | | Stress UI: 4.0 [2.3–4.9]
| UI measured by asking subjects about leakage caused by coughing or sneezing, moving, lifting, sleeping, sexual intercourse, urgency, and rest. Stress UI defined as leakage caused by exertion (coughing or sneezing, moving, or lifting) and urge UI as leakage associated with urgency; UI categorized as leakage occurring weekly or more | 20.4% aged 50 | | | | Urge UI: 2.7 [2.0–3.4]
| | 19.1% aged 55 | | | | Remission at 1-year:
| | 17.6% aged 60 | | | | Stress UI: 41.4% [39.2–43.6]
| | Ethnicity: not reported | | | | Urge UI: 42.0% [39.8–44.1]
| | Residence: one rural (Storstrøm) and one urban county (Copenhagen) in Denmark | | | | Progression from baseline:
| | | | | | Never at baseline to: 69.0% never, 28.9% sometimes, 1.4% weekly or more, 0.7% daily or more
| | | | | | Sometimes at baseline: 11.8% never, 79.8% sometimes, 7.6% weekly or more, 0.8% daily or more
| | | | | | Weekly or more at baseline: 4.5% never, 46.9% sometimes, 39.9% weekly or more, 8.6% daily or more
| | | | | | Daily or more: 0.8% never, 20.6% sometimes, 31% weekly or more, 47.6% daily or more
Samuelsson, 2000 ^38^ | All women scheduled for a gynecological health examination by midwives in primary health care district during 1 year were mailed a questionnaire. Exclusions: pregnant or lactating, a cervical smear in the last year, or mental retardation. Response rate: 77% (n=491) Follow-up: 87.8% (n=382) | Age: 20–59 years old. | | | | 292 continent women at baseline: 40 became incontinent, 252 remained continent
Prospective cohort | Data source: Self-reported postal questionnaire. (Also for follow up). | Gender: Female | | | | 90 incontinent women at baseline, 25 became continent, 65 remained incontinent
Adjusted by: | UI as yes to, “Do you suffer from involuntary loss of urine?” Stress incontinence as, “leakage during effort,” and urge incontinence as, “leakage with sense of urge.” Mixed incontinence was presence of both. Unspecific incontinence as, “leakage, but not during effort or with sense of urge.” | Race: Not reported | | | | Incidence of any degree of UI during follow-up was 40/292 (13.7%)
Age | | Ethnicity: Not reported | | | | Annual incidence of U (any, once a week or more often)I:
Marital status | | Residency: Sweden | | | | 20–29 years: 1.5%, 0.60%
Education | | | | | | 30–39 years: 3.5%, 0.24%
Smoking | | | | | | 40–49 years: 2.9%, 0.81%
Parity | | | | | | 50–59 years: 3.3%, 0.41%
BMI | | | | | | 60–69 years: 3.9%, 0.79%
Diabetes | | | | | | Overall: 2.9%, 0.51%
Hypertension | | | | | | Note: if pregnant women were excluded, the annual incidence would have been 2.7%, with mean annual incidence rate of weekly or more UI as 0.36%
Asthma | | | | | | UI frequency of incident cases:
Neurological disease | | | | | | Seldom: 70%
Oral contraceptives | | | | | | At least monthly: 12.5%
Hysterectomy | | | | | | At least weekly: 12.5%
Level of evidence: II-2C | | | | | | Daily: 5.0%
| | | | | | Number of women developing UI type by type of UI at baseline:
| | | | | | None: 25 stress UI, 5 mixed UI, 4 urge UI, 6 Nonspecific UI
| | | | | | Stress UI: 18 None, 24 stress UI, 7 mixed UI, 4 urge UI, 3 nonspecific
| | | | | | Mixed UI: 1 none, 5 stress UI, 2 mixed UI, 0 urge UI, 0 nonspecific;
| | | | | | Urge UI: 0 None, 2 stress UI, 1 mixed UI, 2 urge UI, 1 Nonspecific
| | | | | | Nonspecific: 6 None, 6 stress UI, 0 mixed UI, 2 urge UI, 6 Nonspecific
| | | | | | Characteristics of women who became incontinent (n=40) vs. those who remained continent (n=252):
| | | | | | Maximum birth weight was heavier (P <.05) and on estrogen treatment (P < .01). Variables tested but not significantly different between the two groups were: age, current smokers, BMI, parity, delivery during follow-up, prior episiotomy, poor pelvic floor muscle strength, instruction in pelvic floor exercises, any disease, number of symptoms reported number of symptoms, hysterectomy, cystocele, vaginal atrophy, fragile vaginal mucous membranes, vaginal pH, and estrogen treatment started during follow-up were not significantly different between women rem
| | | | | | Remission rate: 27.8% over 5 years, mean annual remission rate: 5.9%
| | | | | | 20–29 years: 10.6ˆ
| | | | | | 30–39 years: 8.5%
| | | | | | 40–49 years: 6.4%
| | | | | | 50–59 years: 5.7%
| | | | | | 60–69 years: 2.7%
| | | | | | Remission by frequency of UI at baseline:
| | | | | | Seldom: 6.6%
| | | | | | Monthly: 6.6%
| | | | | | Weekly: 3.6%
| | | | | | Daily: 0
| | | | | | Remission by UI type at baseline:
| | | | | | Stress UI: 6.8%
| | | | | | Urge UI: 0
| | | | | | Mixed UI: 2.7%
| | | | | | Unspecified: 6.4%
Hojberg, 1999 ^39^ | Subjects were selected from all women attending routine antenatal care from January 1993 to April 1996 at the Department of Obstetrics and Gynecology, Aarhus University Hospital. The subjects were asked to fill out a questionnaire at 16 weeks of gestation. | Age: | | | | Prevalence:
Cross-sectional | Response rate: 91% (n=7,795) | 15–24: 17.3% (n=1,347) | | | | Overall:
Adjusted by: Age, parity, BMI, smoking, previous abortions, lower abdominal or urological surgery | Data source: Self-administered questionnaires. | 25–29: 41.7% (n=3,253) | | | | 8,900/100,000 (8.9%)
Level of evidence: III | Urinary incontinence was defined as, “Involuntary loss of urine within the last year.” | 30–34: 30.3% (n=2,365) | | | | By Type:
| Stress incontinence was defined as, “Involuntary loss of urine during physical exertion.” | 35+: 10.6% (n=830) | | | | Stress incontinence: 5,000/100,000 (5%)
| Urge incontinence was defined as, “involuntary loss of urine associated with a strong desire to void.” | Gender: Female | | | | Urge incontinence: 700/100,000 (0.7%)
| Mixed incontinence was defined as, “A combination of stress and urge incontinence.” | Race: Not reported | | | | Mixed incontinence: 2,400/100,000 (2.4%)
| | Ethnicity: Not reported | | | | By Severity:
| | Residency: Denmark | | | | 3,000 / 100,000 (3%) (Reported stress or mixed UI at least once a week)
Sgadari, 1997 ^40^ | Subjects were selected using data from a cross-national database. The interRAI data-base of nursing home assessments was used, containing information on the countries of Denmark, France, Iceland, Italy, Japan, Sweden, and the USA. The data within the interRAI are population-based for the USA, Denmark, and Iceland. The data from the remaining countries are “likely to be representative, but not as broadly-based.” | Age: | | | | Prevalence of urinary incontinence:
| Response rate: Not reported. Data comes from a pre-existing data set. (n=279,191) | Denmark: | | | | By country:
| Data source: Nursing home MDS/Resident Assessment Instrument (RAI). MDS items measuring UI have “been proved to be valid.” | <75: 15.1% | | | | Denmark: 52,200 / 100,000 (52.2%)
| A resident was considered incontinent when they had, “any uncontrolled leakage of urine, regardless of amount, that occurred two or more times a week.” | 75–84: 34.8% | | | | France: 65,200 / 100,000 (65.2%)
| | 85+: 50.1% | | | | Iceland: 56,500 / 100,000 (56.5%)
| | France: | | | | Italy: 54,400 / 100,000 (54.4%)
| | <75: 25.2% | | | | Japan: 42,900 / 100,000 (42.9%)
| | 75–84: 30.5% | | | | Sweden: 61,600 / 100,000 (61.6%)
| | 85+: 44.3% | | | | USA: 46,400 / 100,000 (46.4%)
| | Iceland:
| | <75: 11.2%
| | 75–84: 37.3%
| | 85+: 51.5%
| | Italy:
| | <75: 18.2%
| | 75–84: 42.4%
| | 85+: 39.3%
| | Japan:
| | <75: 18.6%
| | 75–84: 46.3%
| | 85+: 35.2%
| | Sweden:
| | <75: 18.3%
| | 75–84: 38.1%
| | 85+: 43.5%
| | USA:
| | <75: 18.9%
| | 75–84: 33.9%
| | 85+: 47.2%
| | Gender: Male and female
| | Denmark:
| | Male: 23.8%
| | Female: 76.2%
| | France:
| | Male: 30.1%
| | Female: 69.9%
| | Iceland:
| | Male: 32.9%
| | Female: 67.1%
Herzog, 1990 ^41^ | Subjects were all non-institutionalized persons ≥60 years in a stratified probability sample. | Age: 60 years and older | | | | | 1 year incidence rate | 2 year incidence rate
Prospective cohort | Response rate: 66% (n=1,956) | Gender: Male and female | | | | Male | 9.0% | 10.60%
Adjusted by: | 1 year followup: 69% | Males: 41% | | | | Stress | 2.2% | 2.40%
Age | 2 year followup: 72% | Females: 59% | | | | Urge | 9.1% | 10.60%
Sex | Data source: At home interviews conducted by interviewers trained at the U of Michigan School of Public Health. | Race: Not reported | | | | Mixed | 4.9% | 4.30%
General health status | Incontinence was defined as, “any uncontrolled urine loss within the 12 months prior to the interview.” | Ethnicity: Not reported | | | | Other | 5.1 | 5.90%
Level of evidence: II-2C | | Residency: Washtenaw County, Michigan | | | | Female | 22.40% | 20.20%
| | | | | | Stress | 13.7 | 17.40%
| | | | | | Urge | 3.6 | 4.10%
| | | | | | Mixed | 26.8 | 27.60%
| | | | | | Other | 3.9 | 3.60%

Table F1-b Risk factors for urinary incontinence in adults

Author | Subject Selection, Response Rate, Data Source, Measurement Methods (survey, screening, case finding, definition) | Subject Age, Gender, Race, Ethnicity, Residency | | | | Levels of Risk Factors | Incidence of Urinary Incontinence, Overall; by Type, Severity, and Impact on Life
Sample
Bluestein, 2007 ^42^ | Random sample of 262 patients from 400 mailed surveys from 1,327 potential patients older than 65 years in urban settings | Patients divided into two groups - robust health or impaired health. The following are totals for both groups out of 262 patients | | | | | 48.5% vs. 34.6%
Cross sectional survey | Random sample of 1,327 patients with a response rate 70.5% | Mean age: 72.8 163 women; 99 men | | | | | 54 reported incontinence in the robust health group (160)
II-2A | Excluded dementia | Depression: 59 | | | | | 48 reported incontinence in the impaired health group (102)
Listed as excluded in endnote | | Memory loss: 82
| | Weight loss: 58
Boyington, 2007 ^43^ | 1999-2002 CMS MDS | 82.4% Caucasians | | | | Age | 8.9% increase between admission and post admission UI prevalence 65.4% (62,697) vs. 74.3% (71302)
II-3 | Southeastern US region Nursing Homes (AL, FL, GA, KY, NC, SC AND TN.) | 76.5% women | | | | Gender | Caucasians had a greater increase in UI prevalence post admission (9.4%) compared to African Americans (6.9%); however, prevalence for African Americans was higher at both time points.
| Repeated measures, two time period design | mean age - 82.71 years | | | | Education
| Excluded use of a catheter, admission to NH prior to 1999, age <65 or race other than Caucasian or African American. | Cognitive impairment score of 2.06 +/- 1.84 on admission | | | | Morbidities: Alzheimer's, diabetes, stroke, HTN, CHF, Dementia
| 95,911 African American and Caucasian patients | | | | | Bed mobility
| UI measured at 5 levels (0–4) | | | | | Cognitive and functional status
Danforth, 2007 ^44^ | Nurses' Health Study of women ages 54–79 from 14 US states | Mean age 65.9 range 54–79 years | | | | All multivariable logistic regression models included the following covariates: | 2,355 cases of incident UI increase in level of total physical activity was associated with decrease UI
Prospective, observational study | Prospective analysis from 2000 to 2002 | Incontinence by race or risk factors not reported | | | | Race | 15–20% lower risk of developing UI compared with the lowest quintile
Nurse's Health Study | 2,355 cases of incident UI self reported from questions | | | | | BMI | 26% lower risk in the top quintile of walking compared to the lowest quintile (95% CI 0.63–0.88)
II-2A | “Have you leaked urine in last 12 months or lost control?” | | | | | Parity | SUI: 791 cases
| Incident frequent incontinence defined as those reporting at least weekly in 2002 | | | | | Smoking | Urge: 335 cases
| Estimated OR | | | | | HRT usage | Mixed: 440 cases
| Excluded women missing info on incontinence or who reported prevalent incontinence in 2000. | | | | | | Higher levels of physical activity associated with decreasing SUI.
| Excluded major neurological diseases (stroke) or functional limitations (walking, etc.) | | | | | | No relation between activity and other types.
Goldacre, 2007 ^45^ | NHS women admitted for UI; SUI only from 1979 | Total self harm and depression with subsequent UI | | | | Self harm | Risk of admission for self harm high in women with UI 20–44; and significantly high 20–44 recorded as having SUI.
Rate ratios for self harm and depression in a cohort of women admitted for UI, and rate ratios for UI in cohorts of women admitted with self harm or depression compared with a control cohort. | Oxford record-linkage study (ORLS) from 2 health districts from 1968 (no end date) 6 districts from 1974 (no end date) all districts from 1983 (no end date) | Self harm | | | | Depression | 16,882 women in cohort study of self harm and depression ages 20–44, 4,296 ages 45–64; 1,702 age >65. Self harm was significantly high ages 20–44 before their first admission for UI overall OR, 1.41; 1.23–1.61 and before UI coded anywhere in the record as SUI (1.34; 1.15–1.56)
II-2C retrospective study with concurrent controls | In addition, psychiatry data were recorded from 1968-1994. SUI pts only from 1979 on but no end date given. Database had records from these dates until; March 31, 1999 | 16,882 women 20–44 years had self harm | | | | Age | 10,646 women with depression 20–44, 6,557 ages 45–64 and 7,137 65–84. UI significantly high in all three groups RR 1.29 (1.10–1.51), 1.38 (1.15–1.65) and 1.48(1.20–1.81)
| Excluded age <20 or >85 and women who had UI recorded at the same NHS contact episode as self harm or depression | 4,296 women 45–64 years | | | | Women | Significant association at an interval ≤5 years between depression and subsequent UI RR 1.46; 1.33–1.75; ≥5 years depression and UI 1.20;1.05–1.35 and depression and subsequent SUI 1.23; 1.05–1.43
| | 1,702 women ≥65
| | Depression
| | 10,646 women 20–44 years had depression
| | 6,557 women 45–64 years
| | 7,137 women ≥65
Huang, 2007 ^46^ | Observational study of 6,361 community dwelling women ages 65 and older participating in the Study of Osteoporotic Fractures from 1986-1988 | Age: mean age 76.7± 4.7 years | | | | All women recruited | By visit 4, 31% of women reported at least weekly incontinence; 5% reported disruptive incontinence
II-2A | Restricted to patients who gave data on cognitive, physical function and UI through visit 4 | | | | | Depression:7% | No data before this time or for subsequent visits.
| Excluded abnormal cognitive and physical function at baseline | | | | | BMI: <25 - 42%; 25–30 - 37%; >30 - 21%
| Self administered questionnaire “in last 12 months, have you ever leaked urine or lost control?” | | | | | History of hysterectomy: 39%
| | | | | | CHF: 3%
| | | | | | Parity: 0 births - 20%; 1 birth - 12%; 2 births - 23%; >3 - 45%
| | | | | | Diabetes: 6%
| | | | | | Stroke: 5%
| | | | | | Parkinson: <1%
| | | | | | Alcohol use: 3%
Jacobsen, 2007 ^47^ | All men with localized prostate cancer scheduled for either open retropubic or laparoscopic prostatectomy at University of Alberta between Oct 1999–July 2002 | RRP compared to LRP at 2 points | | | | RRP | Despite subject claims, 4% of patients in RRP had incontinence and 3.5% in LRP at baseline.
Prospective study of men | Exclusion: prior pelvic radiotherapy, subjective complaint of incontinence at baseline or neurological impairment known to affect bladder | RRP | LRP 1^st^ half | LRP 2^nd^ | | LRP | Mean gm weight
II-2A | Post evaluation included 24 hour pad test and voiding diary performed at 3 and 12 months. I-PSS completed at 3–6–9–12 months | # pts | | | | Surgery | Post op
| UI defined as total pad weight gain of more than 8gm during 24 hours. To control affect of activity, subjects recorded activity for baseline pad test and repeated this activity as closely as possible for subsequent pad tests. | 148 | 29 | 28 | | | RRP | LRP 1^st^ | LRP 2^nd^
| | Age | | | | | 3 months
| | 63.7 | 62.3 | 60.9 | | | 34.9 | 28 | 49.6
| | Mean BMI | | | | | 12 months overall
| | 28.1 | 26.87 | 27.54 | | | 8.2 | 9.6 | 6
| | % smokers | | | | | 12 months UI
| | 14.9 | 10.3 | 7.1 | | | 34.8 | 24.5 | 12.2
| | | | | | | % Incontinent
| | | | | | | 3 months
| | | | | | | 42 | 70.4 | 60
| | | | | | | 12 months
| | | | | | | 12.8 | 20.7 | 14.3
Smither, 2007 ^48^ | U.S. men, 203 consecutive patients who underwent radical prostatectomy by a single surgeon. Walsh technique used. | Age range 40–72 mean 58 | | | | RRP | Mean pad weight (range, SD)
Prospective consecutive patients | Patients instructed in pelvic floor exercises preop with no other interventions. No data on compliance reported. | Preop PSA range .3–25.4 mean 7.3 | | | | | 2 weeks: 36.7 (0–241.8; 40.5)
No controls | Dates of study: 3/98–8/03 | Localized cancer | | | | | 6 weeks: 21.9 (0–226; 39.5)
| 1 hour pad test used on post op visits | | | | | | 18 weeks: 5.6 (0–76; 4.2)
| Gram weight of urine loss was recorded and subdivided into 4 groups - minimal loss <1g; mild >1, <10; moderate 10–50g and severe >50g. | | | | | | 30 weeks: 2.6 (0–80.4; 10.6)
| Post op visits at 2 weeks, 6, 18, 30, 42 and 54 weeks. | | | | | | 42 weeks: 2.8 (0–104.5; 14.1)
| Did not use patient estimates of pad usage at home | | | | | | 54 weeks:1.7 (0–71.1; 8.9)
| No mention if incontinence before surgery | | | | | | 18 week marker appears to be the time point which the majority of patients achieved urinary control, such that at 30 weeks,.85% of patients fit in the minimal incontinence category, and by 54 weeks, 91% are in that category.
Waetjen, 2007 ^49^ | Study of Women's Health Across the Nation (SWAN) 1995-2001 Multidisciplinary cohort study of menopausal transition | 3,302 women at baseline, 599 dropped out or did not complete UI questions (18.1%) | | | | Race | Compared to Caucasians; African American, Chinese, Japanese, and Hispanic women had lower odds of reporting frequent prevalent incontinence; no sign trend in reporting of any or frequent incident incontinence by racial ethnic group. Parity, diabetes, uterine fibroids, depression and poor social support were significantly associated with prevalent but not incident incontinence. Significant interaction between education and both Chinese and Japanese ethnicity. Lower level of education associated with less prevalent incontinence (Chinese - OR = .33 95% CI .17, .69; for Japanese - OR .48, 95% CI .25, .97.
Prospective cohort | 7 clinical sites (Boston, Chicago, Detroit, LA, Newark, Pittsburg, Oakland, CA) community based women ages 40–55 years each site recruited one Caucasian group and one minority group - African American, Japanese, Chinese and Hispanic | baseline | | | | Ethnicity | Being either a smoker or past smoker associated with increased odds of incident incontinence in African
II-2A | Exclusion: no menstrual period in more than 3 months, hysterectomy and/or bilateral oophorectomy, use of oral contraceptives, estrogens or progestins | mean age: 45.8 | | | | SES | Americans but not other racial groups.
| Interview and self administered questionnaire | Caucasian: 47% | | | | Obstetric history | Diabetes was the strongest risk for prevalent incontinence and highest in Caucasians.
| “In the past year, have you ever leaked even a small amount of urine involuntarily?” | African Americans: 28.3 | | | | Smoking | See supplemental table.
| Defined any incontinence: at least monthly | Japanese: 8.5 | | | | Medication use
| SI: urge to void and can't reach toilet fast enough | Hispanic: 8.7 | | | | Educational level
| Combined less than once a month incidents with “no incontinence” | Premenopausal: 46.5 | | | | Depression
| | Early perimeno: 53.5 | | | | Physical activity
| | | | | | BMI
Adelmann, 2004 ^50^ | Community UI prevalence sample of 910 persons to a 1998-1999 survey enrolled in a Medicaid managed health plan | Characteristics of community and nursing home N=910 | | | | Race | Prevalence of UI in community sample
Prospective cohort | Seven county Minneapolis-St. Paul metro area | | Community | NH (%) | | Age | | Ever/current | Past week
| Age ≥65 | Women | 82.1% | 79.2 | | Gender | UI (%)
| Random sample of 910 persons enrolled in Medicaid health plan. Of this the n= 378 that were eligible due to UI. Sample was further limited to persons based on at least one claim for a doctor's visit and medical chart could be located. n=236 | Men | 17.9 | 20.8 | | | Total | 41.6 | 23
| Nursing home abstraction sample was randomly drawn from Medicaid persons for a total of 480 persons. | Age | | | | | Women | 45 | 25.5
| Interviews face to face in residence. Response rate 59%, cooperation rate 90%. | 65–74 | 50% | 14 | | | Men | 25.8 | 11.7
| Abstraction of medical record at clinics also. | 75–84 | 34.9 | 34.2 | | | Age
| Definition: ever/current UI measured by a yes response to questions about trouble holding urine or leaking urine | 85+ | 15.1 | 51.9 | | | 65–74 | 34.1 | 17.6
| | Mean | 75.9 | 84.5 | | | 75–84 | 45 | 26.2
| | Race | | | | | 85+ | 58.1 | 33.8
| | White | 69.4 | 93.8 | | | Race
| | Black | 14.5 | 4.6 | | | White | 45 | 25.5
| | Other | 16.2 | 1.7 | | | Black | 39.8 | 20.3
| | | | | | | Other | 30.1 | 16.1
| | | | | | | Subgroup report by race and age Race among women (self report)
| | | | | | | | p<.003 | p<.016
| | | | | | | White | 49 | 28.7
| | | | | | | Black | 43 | 22.4
| | | | | | | Other | 31.9 | 16.4
| | | | | | | | p,.001 | p<.001
| | | | | | | 65–74 | 37.4 | 20.4
| | | | | | | 75–84 | 47.7 | 27.6
| | | | | | | 85+ | 62.1 | 36.3
| | | | | | | Age among Whites
| | | | | | | | p<.001 | p<.001
| | | | | | | 65–74 | 35.3 | 19.5
| | | | | | | 75–84 | 49.8 | 27.7
| | | | | | | 85+ | 59.1 | 35.7
| | | | | | | Age among Blacks
| | | | | | | | p<.037 | p<.021
| | | | | | | 65–74 | 34.1 | 14.6
| | | | | | | 75–84 | 46.2 | 28.2
| | | | | | | 85+ | 71.4 | 57.1
| | | | | | | Age among White women
| | | | | | | | p<.001 | p<.005
| | | | | | | 65–74 | 39.1 | 22.9
| | | | | | | 75–84 | 53.1 | 30.3
| | | | | | | 85+ | 62.3 | 37.7
| | | | | | | Age among Black women
| | | | | | | | p<.044 | p<.050
| | | | | | | 65–74 | 36.4 | 16.7
| | | | | | | 75–84 | 50 | 29.4
| | | | | | | 85+ | 71.4 | 42.9
| | | | | | | Medically detected UI in community and nursing home samples
| | | | | | | | Community | Nursing Home
| | | | | | | | Past 18 months | Past 12 months
| | | | | | | Total | 22.3% | 77.2%
| | | | | | | Gender | p=.278 | p=.174
| | | | | | | Age in years | p.868
| | | | | | | | p<.001
| | | | | | | 65–74 | 61.2%
| | | | | | | 75–84 | 75%
| | | | | | | 85+ | 82.7%
| | | | | | | race also insignificant p
| | | | | | | Prevalence of medically treated UI
| | | | | | | | Community | Nursing Home
| | | | | | | | Past 18 months | Past 12 months
| | | | | | | any type | 64.8% | 6.5%
| | | | | | | SI | 38.9% | 3%
| | | | | | | Urge | 9.3 | 0.
| | | | | | | Other | 5.6 | 2.4
| | | | | | | Mixed | 11.1 | 0.3
Andersson, 2004 ^10^ | Swedish population, both men and women ages 18–79 years (Orebro county) in March 2000 | 7,680 females | | | | Age | Prevalence reported by age and gender for weekly
Population based study | Questionnaire mailed to home comprising 12 questions on UI as a supplement to a large public health survey on health and general living. Mailed to 15,360 randomly selected residents out of 274,000 population in this county. | 7,680 males | | | | Gender | Women (men)
II-3 | Response rate 64.5% | Age | categories | | | | Women (men)
| Used definitions from ICS | 18–35 | 53.9% | | | | 18–34 - 3 (1); 35–49 - 10 (2); 50–64 - 13(3); 65–79 - 21(8).
| Stats on weights and calibration and found results were the same | 35–50 | 60.3 | | | | Total for weekly
| | 50–65 | 69.6 | | | | Women - 11% Men 3%
| | 65–80 | 72.2 | | | | SI total for women 77%, men 13%
| | Life and Health questionnaire sent to 70,000 residents randomly selected. | | | | | 18–34 - 59(18); 35–49 - 83(13); 50–64 - 83(11); 65–79 - 71(13)
| | In Orebro, pop of 274,000, one of the five counties that participated in above study, a special section on UI was given to a sample of 15,360 residents | | | | | Urge Incontinence for women 46%; men 45%
| | | | | | | 18–34 - 42(18); 35–49 - 38(37); 50–64 - 48(43); 65–79 - 53(59)
| | | | | | | Women more affected than men
| | | | | | | Proportion of people with UI increased markedly with age
| | | | | | | | At least 1/week | At any time
| | | | | | | Women | 11% | 27%
| | | | | | | 18–34 | 3 | 10
| | | | | | | 35–49 | 10 | 26
| | | | | | | 50–64 | 13 | 37
| | | | | | | 65–79 | 21 | 39
| | | | | | | Men | 3% | 10%
| | | | | | | 18–34 | 1 | 3
| | | | | | | 35–49 | 2 | 6
| | | | | | | 50–64 | 3 | 13
| | | | | | | 65–79 | 8 | 21
| | | | | | | | SI | Urge
| | | | | | | Women | 77 | 46
| | | | | | | Men | 13 | 45
| | | | | | | Duration of UI years
| | | | | | | <1 | 24%
| | | | | | | 1–5 | 51
| | | | | | | 6–10 | 14
| | | | | | | >10 | 11
Bogner, 2004 ^11^ | ECA (Epi Catchment Area) program was used to sample from Baltimore to include 3,481 persons selected from East Baltimore for this study. | Mean age of study sample was 67.2 | | | | Age | 22% Whites reported UI
Population based longitudinal survey | Community dwelling adults who were initially living in East Baltimore in 1981. | 64% were women | | | | Gender | 13% of Blacks reported UI
II-2B | Out of 3,481 persons, 1,920 were contacted (73% of original cohort). Study sample included 822 persons aged ≥50 who completed info on UI. After exclusions for missing data, 747 were the final sample. | 72.3% White; mean age 68.2 ± 11 | | | | Functional status | 19.8% reported UI during the year preceding the interview
| African Americans and Whites aged ≥50 at followup interview performed 1993-1996 | 27.7% AA - mean age 64.5 ± 10 | | | | Cognitive status | | White (540) | Black (207)
| Age ≥65 were over sampled | | White | Black | | Chronic medical conditions-diabetes, heart trouble, stroke, arthritis or cancer | UI | 22.4% | 13%
| GHQ used and self report on UI | Diabetes | 14.3 | 16.9 | | Race | No information on SI, Urge Incon.
| UI = “Have you ever had any difficulty in controlling your water, losing your urine or having trouble getting to the bathroom on time?” If any uncontrolled urine loss was reported within the 12 months before the interview, persons were classified as having UI. | Heart trouble | 27.4 | 26.6 | | | Association between UI and Psychological Distress
| | Arthritis | 51.1 | 56.5 | | | Crude | Adjusted OR (95% CI)
| | Stroke | 8.2 | 7.3 | | | White
| | Cancer | 14.4 | 6.3 | | | 1.28 (.76–2.14) | 1.07 (.62–1.84)
| | MME | 27.6±2.6 | 25.6±3.6 | | | Black
| | ADL impaired | 1.9% | 3.9% | | | 4.22 (1.72–10.39) | 5.6 (1.88–16.67)
Corcos, 2004 ^12^ | Canadian population ≥35 | 48.2% men; mean age 52 | | | | Gender | Wet OAB markedly higher in both men and women over age 75 years
Prospective cohort | Stratified by census of metro area and by gender. 7,487 persons were sample base. 53.7% response rate. | 51.8% women; mean age 50.9 | | | | Age | No correlation observed between age and prevalence of mixed OAB in women whereas linear relationship was noted in men
No control mentioned | 3,249 interviews from Montreal, Toronto, Vancouver, and Edmonton were final sample | 82.4% younger than 65 and 17.6% older
| Investigators developed standardized questionnaire to ascertain OAB and SUI and impact on quality of life.
| Computer assisted telephone interviews conducted in 2 steps: an initial questionnaire evaluate presence of OAB followed by detailed questionnaire completing the assessment.
Dallosso, 2004 ^13^ | Part of the Leicestershire MRC Incontinence Study. This study focused on women living in the community in UK ages ≥40. | Baseline data compared to those who provided FFQ data. Median age 57 vs. 61. Rating of health poorer in baseline after adjusting for age (OR: 1.66; 95% CI 1.51–1.82). More longterm health problems in baseline (OR 1.14; 95% CI, 1.05–1.25). No difference in reporting SUI (OR: 1.02; CI 95%, .92–1.13) | | | | BMI | Incidence at 1 year followup
Prospective longitudinal study | A random sample of 20,244 women drawn, 12,565 returned the questionnaire (65% response rate). | | | | | Fat intake | | Total N | SUI cases
II=2B | FFQ sent to 10,852 of above sample. 7,46 completed it (response rate 65%) | | | | | Vitamin usage | %
| 1^st^ postal questionnaire mailed Oct 1998 and completed by 7,046 women. 2^nd^ postal questionnaire mailed Oct 1999 and completed by 6,424 women (91% response rate). | | | | | Cholesterol and other dietary factors | 40–49 | 1,242 | 9.3
| Excluded women living in residential or nursing homes | | | | | Age | 50–59 | 1,272 | 7.2
| Excluded those of South Asian origin who make up 5.3% of Leicestershire pop over 40 years. | | | | | | 60–69 | 1,108 | 7.6
| Used ICS definitions | | | | | | 70–79 | 756 | 8.3
| | | | | | | 80y + | 214 | 12.6
| | | | | | | only significant p abstracted - others in article not significant
| | | | | | | Total fat
| | | | | | | OR (95% CI) Q2-Q5
| | | | | | | 1.38(.89–2.13); 1.35(.88–2.08); 1.27(.83–1.94); 2.02 (1.33–3.05) p=.02
| | | | | | | Saturated fat
| | | | | | | 1.08(.69–1.69); 1.46(.96–2.22); 1.08(.7–1.67); 2.02(1.35–3.03) p = .001
| | | | | | | Carbs
| | | | | | | .95(.65–1.38); .68(.46–1.01); .59(.39-.9); .73(.49–1.08) p=.05
| | | | | | | Cholesterol
| | | | | | | 1.09(.70–1.69); 1.24(.81–1.9); 1.34(.88–2.04); 2.09(1.4–3.14) p=.003
| | | | | | | after adjusting for BMI, fat unchanged but carbs were no longer sig p=.07
| | | | | | | 3 vitamins associated with SUI
| | | | | | | Vit B12
| | | | | | | Zinc
| | | | | | | Retinol was marginal
| | | | | | | After adjusting for BMI, association with B12 remained + while zinc was no longer sig.
de Tayrac, 2004 ^31^ | French women - study population 717 who had Dargent and Rudigoz technique 449 did not respond 365 (50.9%) returned questionnaires 51 excluded leaving 314 women | Vaginal hyst. | Control group | | | Age | Prevalence (as stated in article)
Case control, retrospective study | 117 patients who had a vaginal hysterectomy for menorrhagia from Jan 1991 to Dec 2001 control group of 116 patients who had conservative treatment | Age | | | | Parity | | Vag hyster % | Control %
II-3 | 197 had hysterectomy for pelvic pain and 117 for menorrhagia | 51.4 | 50.9 | | | Menopausal status | Freq day>8 | 19.7% | 16.4%
| self report questionnaire | Parity | | | | Smoking | Noc: day >1 | 5.1 | 6.9
| | 2.1 | 2.2 | | | Volume of drink | Urgency | 62.4 | 54.3
| | Menopause | | | | Did not report incidence by each of these | Qmo | 36.8 | 30.2
| | 43.5% | 47.4% | | | | Qwk | 19.7 | 12.1
| | Smoking | | | | | Qday | 6 | 12.1
| | 17.9% | 17.2% | | | | UI | 39.3 | 33.6
| | Drink >2 L/day | | | | | Use of pads | 15.4 | 12.9
| | 7.7% | 9.5% | | | | Urge Inc | 20.5 | 13.8
| | History of uro sxs | | | | | Qmonth | 12 | 7.8
| | 0 | 0 | | | | Qweek | 4.3 | 5.2
| | | | | | | Qday | 4.3 | 0.9
| | | | | | | SI | 36.7 | 31.9
| | | | | | | Qmonth | 18.8 | 16.4
| | | | | | | Qweek | 12.8 | 8.6
| | | | | | | Qday | 4.3 | 3.5
| | | | | | | Age <60 | VH | Control
| | | | | | | UI | 41.8% | 33.7
| | | | | | | Urge Incon | 21.8 | 12.5
| | | | | | | SI | 40 | 33.7
| | | | | | | Age >60
| | | | | | | UI | 28.6 | 41.7
| | | | | | | Urge Incon | 14.3 | 25
| | | | | | | SI | 28.6 | 33.3
Deliveliotis, 2004 ^15^ | 283 Greek men from 441 patients enrolled. | Mean ages | | | | Types of surgery | RRP; TURP; pretreatment; post treatment
Prospective cohort | 105/142 patients treated with RRP for prostate cancer | 67.4 range 55–75 group 1 | | | | | Urinary fun
II-2A | 98/151patients treated with TURP for BPH | 70.3 range 58–74 group 2 | | | | | 85.1; 80.2; .121; 71.2; 87.3; .005
| 80/148 healthy men as control completed surveys | 72.4 range 62–82 control | | | | | Urinary bother
| used AUA Sx Index, UCLA Prostate Cancer Index; Rand 36- Item Health Survey and BMSFI translated into Greek | HRQOL post treatment | | | | | 85.1; 70.6; .021; 65.1; 80.2; .003
| Patient outcomes 2 years post treatment compared to pretreatment status at 2 weeks prior to treatment | RRP | TURP | Control | | | AUA SI
| investigators felt poor returns due to length of questionnaires and the number of them | Physical functioning | | | | | 11.1; 8.6; .812; 24.2; 8.2; .001
| | 81.5 | 78.1 | 82.3 | | | UI every day
| | | | | | | 2%; 9%; .002; 12%; 2.78%; .002
| | | | | | | RRP had trend towards worse urinary function 2 years after surgery but difference not significant. Urinary bother deteriorated.
| | | | | | | UI in control group was 5.78%
Foldspang, 2004 ^51^ | 6,240 and 6,468 women ages 20–59 years analysis based on 1,232 women in combined samples who reported their 1^st^ and last childbirth within 13–120 months prior to responding to the questionnaire so minimum followup period after childbirth was 12 months | C-section in 12.2% of 1^st^ childbirths Average age: 32.8 years (20–41) 52.1% reported having 2 births or more | | | | Mode of delivery # of children | Risk of postpartum UI depending on UI during pregnancy
Age stratified random samples | Self questionnaire mailed Jan–March 1995 and 1998 67.8% responded | Mean age at 1^st^ birth = 27.5 years and 29.9 years at 2^nd^ | | | | Characteristic of group analyzed First childbirth(n=1232) | Adjusted OR
II-2A | | Average duration since 1^st^ childbirth was 5.3 years | | | | With index pregnancy UI; vaginal childbirth vs. cesarean section | 2.0 (0.8; 4.9)
| | Denmark | | | | Without index pregnancy UI; vaginal childbirth vs. cesarean section | 5.4 (2.3; 12.4)
| | | | | | Vaginal childbirth index pregnancy; UI vs. no UI during index pregnancy | 8.4 (5.9; 12.1)
| | | | | | Cesarean section; index pregnancy UI vs. no index pregnancy UI | 22.0 (6.8; 70.9)
| | | | | | Second childbirth(n=642) | 1.8 (0.3; 10.5)
| | | | | | With index pregnancy UI; vaginal childbirth vs. cesarean section | 2.7 (0.8; 9.0)
| | | | | | Without index pregnancy UI; vaginal childbirth vs. cesarean section | 20.3 (2.4; 172.4)
| | | | | | Vaginal childbirth; index pregnancy UI vs. no index pregnancy UI | 11.9 (7.3; 19.3)
| | | | | | Cesarean section; index pregnancy UI vs. no index pregnancy UI | Mutually and age-adjusted relative risks (odds ratio, OR) and attributable risks (AR) for postpartum UI by pregnancy UI, vaginal childbirth and parity
| | | | | | Childbirth | OR | Attributable risks (%)
| | | | | | First childbirth (n=1232) | 9.2 (6.5; 13.0) | 56.1
| | | | | | index pregnancy UI Vaginal childbirth | 3.6 (2.1; 6.3) | 69.5
| | | | | | Second childbirth (n=642) | 12.3 (7.6; 19.9) | 67.6
| | | | | | Index pregnancy UI Vaginal childbirth | 2.2 (0.9; 5.7) | 53.0
Fritel, 2004 ^52^ | Women from hospital database of 1^st^ birth women who had not delivered fetus >22 weeks | Table I. Analysis of the differences among responders, women not reached and non-responders concerning potential risk factors for stress urinary incontinence (SUI) | | | | Age at 1^st^ delivery | Table III. Risk factors for SUI 4 years after the first delivery SUI
Retrospective cohort | 307/669 primiparous women who delivered in 1996 in vertex position between 37–41 weeks (274 had moved and 88 did not respond) 45.9% response rate. | Risk factor Responders Not reached Non-responders p | | | | BMI | Risk factor: yes (n=89) no (n=218) p
II-2C | Excluding the women who did not receive the questionnaire (274), response rate was 77.7% | Age at delivery | | | | Birth weight | Age at delivery >30 years: 53.9 (48); 36.7 (80); 0.005
| Mailed questionnaire sent 4 weeks after delivery and asked about SUI before, during, and after pregnancy - “Do you have loss of urine during physical exertion, cough or sneeze?” | 29.3 [4.4]; 28.2 [4.4]; 28.9 [4.7] 0.01 | | | | Duration of labor | BMI >27 kg/m2: 2.2 (2); 4.6 (10); 0.34
| UI categorized slight, mode or severe using Sandvik Index | BMI (kg/m2): 21.3 [2.9]; 21.1 [2.9]; 21.3 [3.2] 0.62 | | | | Duration of second stage | Birth weight ≥4000g 2.2 (2); 1.4 (3); 0.58
| | Birth weight (g): 3240 [384]; 3253 [400]; 3241 [430] 0.92 | | | | Mode of delivery | Labor ≥8 hours: 41.6 (37); 21.1 (46); 0.0002
| | Labor (hours) 6.2 [2.3]; 6.5 [2.5]; 6.6 [2.3] 0.21 | | | | 3^rd^ degree tear at first delivery | Active 2nd stage ≥20 minutes: 16.9 (15); 19.3 (42); 0.62
| | Active 2nd stage (minutes): 11.1 [7.5];10.6 [7.9]; 10.9 [7.9] 0.69 | | | | Second delivery since 1996 | C section: 6.7 (6); 11.5 (25); 0.21
| | C- section: 10.1 (31);17.5 (48);17.0 (15) 0.03 | | | | Urinary leakage before 1^st^ pregnancy | Forceps: 38.2 (34); 35.3 (77); 0.63
| | Forceps: 36.2 (111);31.3 (86); 44.3 (39) 0.08 | | | | Urinary leakage during 1^st^ pregnancy | 3^rd^ degree tear: 2.2 (2); 0.9 (2);0.35
| | Third-degree tear: 1.3 (4); 1.1 (3);1.1 (1) 0.97 | | | | | Leak before pregnancy: 16.1; 0.9 <0.0001
| | France | | | | | Leak during pregnancy: 40.2; 15.3 <0.0001
| | | | | | | 2^nd^ delivery: 69.6 (53); 61.0 (133); 0.81
| | | | | | | Table IV. Risk factors for stress urinary incontinence 4 years after the first delivery
| | | | | | | Risk factor Odds ratio 95% CI p Leakage before the 1st pregnancy 18.7 3.6–96.4 0.0005
| | | | | | | Leakage during the 1st pregnancy 2.5 1.3–4.8 0.005
| | | | | | | Age at the 1st delivery: >30 years: 2.4 1.4–4.2 0.002
| | | | | | | Labor ≥8 hours 3.1 1.7–5.7 0.0002 Cesarean at the 1st delivery: 0.3 0.1–0.9 0.04
| | | | | | | Adjusted odds ratios estimated by logistic regression analysis
| | | | | | | According to multiple logistic regression analysis, the independent risk factors were urine leakage before the first pregnancy [odds ratio (OR) 18.7; 95% confidence interval (CI) 3.6–96.4], urine leakage during the first pregnancy (OR 2.5; 95% CI 1.3–4.8), duration of first labor ≥8 hours (OR 3.1; 95% CI 1.7–5.7), mother's age >30 years at the first delivery (OR 2.4; 95% CI 1.4–4.2) and cesarean section at the first delivery (OR 0.3; 95% CI 0.1–0.9).
| | | | | | | Table III. Risk factors for SUI 4 years after the first delivery
| | | | | | | SUI
| | | | | | | Risk factor: Yes (n=89); No (n=218) p
| | | | | | | Age at delivery >30 years: 53.9 (48); 36.7 (80) 0.005
| | | | | | | BMI >27 kg/m2: 2.2 (2); 4.6 (10) 0.34
| | | | | | | Birth weight ≥4000g: 2.2 (2); 1.4 (3) 0.58
| | | | | | | Labor ≥8 hours: 41.6 (37); 21.1 (46) 0.0002
| | | | | | | Active 2nd stage ≥20 minutes: 16.9 (15); 19.3 (42) 0.62
| | | | | | | C section: 6.7 (6); 11.5 (25) 0.21
| | | | | | | Forceps: 38.2 (34); 35.3 (77) 0.63
| | | | | | | 3^rd^ degree tear: 2.2 (2); 0.9 (2) 0.35
| | | | | | | Leak before pregnancy: 16.1; 0.9 <0.0001
| | | | | | | Leak during pregnancy: 40.2; 15.3 <0.0001
| | | | | | | 2^nd^ delivery: 69.6 (53); 61.0 (133) 0.81
| | | | | | | Table IV. Risk factors for stress urinary incontinence 4 years after the first delivery
| | | | | | | Risk factor Odds ratio 95% CI p
| | | | | | | Leakage before 1st pregnancy: 18.7 3.6–96.4 0.0005
| | | | | | | Leakage during 1st pregnancy: 2.5 1.3–4.8 0.005
| | | | | | | Age at 1st delivery >30 years: 2.4 1.4–4.2 0.002
| | | | | | | Labor ≥8 hours 3.1 1.7–5.7 0.0002
| | | | | | | Cesarean at 1st delivery: 0.3 0.1–0.9 0.04
| | | | | | | Adjusted odds ratios estimated by logistic regression analysis
Grodstein, 2004 ^16^ | Nurse Health Study from 1996-2000 females | Cohort of 39,436 women ages 50–75 | | | | Age | 5,060 incident cases of occasional UI
Prospective cohort | Questionnaire mailed in 1996 to 39,436 women post menopausal women who had no leaking of urine and were followed for 4 years | Mean age 61 for current HRT use; 64 for never used | | | | BMI | 2,495 incident cases of frequent UI
II-2A | Incident cases of occasion UI were defined as leaking 1–3 times per month; frequent were at least once per week | BMI for never used HRT was 27 | | | | Smokers | Average incidence rate of 3.2% per year and 1.6% per year respectively
Confounded for stroke and physical limitations and results were the same in both analysis | Excluded premenopausal women or users of estrogen creams, or reported leaking in 1996 | Current use BMI was 47 and past use for BMI was 47 | | | | Recurrent UTI | 50–55 years yearly incontinence was 3% in those who never took HRT
| | Hormone Use Post Menopause | | | | Diabetes | 56–60 - 3.5
| | Never | Current | Past | | COPD | 61–65 - 3.8
| | Caucasian | | | | Neurological disorders | 66–70 - 4.3
| | 98 | 97 | 98 | | Parity | 71–75 years - 5.3%
| | African American | | | | HRT
| | 1 | 1 | 1
| | Hispanic
| | 0 | 1 | 0
| | Asian
| | 1 | 1 | 1
| | Smokers @ 45% all Hysterectomy
| | 6 | 47 | 40
Groutz, 2004 ^53^ | 363 consecutive primiparae followed for 1 year | Vaginal; Obstructed; Elective C-sec | | | | Age | SUI significant in heavier women - 67±10kg vs. 59±9 kg p=.001 and increase in prevalence during pregnancy 67% vs. 27% p=.003.
Prospective cohort elective C-section without trial of labor vs. vaginal delivery vs. C-section due to obstructed labor | SUI before pregnancy excluded Non-singleton deliveries, instrumental-assisted vaginal deliveries excluded | Delivery; labo; c-sec | | | | Maternal age | Duration of 1^st^, 2^nd,^ and active second stages of labor were stat longer (p<.05) in women who had PP SUI compared to those without P SUI (376 vs. 287min, 121 vs.. 103 min; 61 vs. 43min)
II-2A (if controls are considered types of deliveries) | 145 spontaneous vaginal delivery 100 C-section following obstructed labor with mean cervical dilation of 8.7 ± 1.6cm 118 elective C section | Age: 28±4; 32.5±5.3; 31.7±5.2 | | | | Weight | Older maternal age (36 years vs. 32 years), heavier maternal weight (71kg vs. 63kg) and prevalence of SUI during pregnancy was noted among incontinent vs. continent women
| Interviewed one year PP SUI - involuntary leakage with cough, sneeze, etc | Weight: 60±9; 62.5±11.6; 63±13 | | | | Height
| Regular UI as defined by involuntary excretion or leakage of urine in inappropriate places or times twice or more a month, regardless of quantity loss | Height: 164+/-6/6; 162±5.6; 164±6.7 | | | | Mode of delivery
| | Gestation age: 39.7; 40.2; 38.8
| | Birth weight: 3,251; 3,450; 3,260
| | Israeli women delivered at Tel Aviv Sourasky Medical Center
Hagglund, 2004 ^17^ | 145 incontinent and 193 continent women in year 2000, who had participated in 1995 prevalence study. Response rate 73% (248/338) | Swedish women | | | | Age; 22–50 years | Women continent at baseline incidence
4 year followup cohort study | Of 248 responders at followup, 118 reported UI and 130 reported being continent. | | | | | | 22–30 | 13%
II-2A | Changes in type of UI measured using DIS “do you have problem with involuntary loss of urine?” | | | | | | 31–40 | 16
| | | | | | | 41–50 | 18
| | | | | | | Women incontinent at baseline
| | | | | | | 22–30 | 33
| | | | | | | 31–40 | 18
| | | | | | | 41–50 | 13
Haltbakk, 2004 ^18^ | 480 Norwegian men at St. Olavs Hospital, Trondheim Norway. Tentative diagnosis of BPH made on 612 patients and from this pool, sample analyzed was 480 (78%). | Mean age of patients was 67 years, SD 10.6 years; median 69 years range 39–91 years | | | | Age | 3/4 of men experienced sleeping problems during previous months and 31% had experienced sleeping problems
Prospective cohort no control mentioned ? historical control | ICS LUTS questionnaire (ICS-BPH) between 1997-2000. IPSS, SPI and SISI used also. | 15% mild symptoms | | | | | issues related to altered lifestyle were recognized by 7–90% of men and 47% reported they would be mostly dissatisfied if their current urinary symptoms persisted for rest of life.
| UI defined as any involuntary leakage of urine. | 54% moderate symptoms | | | | | Incontinent group - 64% had sx ≤5 years
| | 31% severe symptoms | | | | | 22% for 5–10 years
| | Mean age in incontinent group was 68 years | | | | | 6% for ≥10 years remaining 8% did not indicate
Holroyd-Leduc, 2004 ^19^ | 6,506 of 7,447 subjects ages ≥70 in the Asset and Health Dynamics Among the Oldest Old study who had complete info on continence status were baseline - outcomes 3 groups- 5,872 nursing home, 5,521 ADL decline and 5,509 IADL decline as outcomes | Mean age ≤SD = 77 (range 69–103) | | | | Age | UI and outcomes adjusted OR (95%CI)
Population based Prospective cohort | Subjects interviewed in 1993 and 1995 | 63% female | | | | Sex | Death: 10.9% .90 (.67–1.21)
Confounders - sex, age, socioeconomic status, race, smoking, alcohol, BMI, sensory impairment, comorbid disease, depression, cognitive function and baseline dependency. | Blacks, Hispanics, and Florida residents were over sampled | 86% White | | | | SES | Nursing home: 4.4% 1.33 (.86–2.04)
II-2A | Overall response rate was 80% | Median number of baseline comorbid medical conditions was 2 | | | | Race | ADL decline: 13.6% 1.24 (.92–1.68)
| UI measured “next question might not be easy to talk about, but it is very important for research on health & aging, during the last 12 months, have you lost any amount of urine beyond your control?” | 10% received help with 1 or more ADLs and 23% were receiving help in 1 or more IADLS at baseline | | | | Smoking/alcohol | IADL decline: 21.2% 1.31 (1.05–1.63)
| | Patients with UI had more comorbidities (p=.001), higher rate of visual impairment (35% vs. 22.4% p <.001) and hearing impairment (39.7% vs. 30.5% p<.001) | | | | BMI | More functionally impaired at baseline
| | Community dwelling in U.S. | | | | Sensory impairment
| | | | | | Comorbidity
| | | | | | Cognitive scores
| | | | | | Depression
| | | | | | ADL
| | | | | | IADL
Hunskaar, 2004 ^20^ | Postal survey mailed to 29,500 households in 4 countries | Age ≥ 18 years | | | | Age | No new cases reported
Cross national study, Prospective | 58.1% response rate 5,976 women with UI included in analysis (35%) | France - 44.8 | | | | Ethnic background | Only prevalence reported by country
No control group | Definitions used by ICS; symptoms in last 30 days and in last 7 days | Germany - 59
| | UK - 45
| | Spain - 64
| | All - 58
Jackson, 2004 ^22^ | 1,017 post menopausal U.S. women ages 55–75 enrolled in HMO and followed for 2 years (1998-2002) inclusion criteria were no natural menstrual cycle in past 12 months. | Frequency of Exposures at Enrollment and University Risk of Symptomatic Urinary Tract Infection | | | | Smoking | Incidence of UTI was .07 per person per year.
Population based Prospective cohort; also randomly selected from HMO diabetes registry | Exclusion: oral estrogen or vaginal estrogen, residential nursing care, restriction to wheel chair, dementia or severe psych disorder, indwelling catheter or intermittent urinary catheter, end stage renal disease requiring dialysis, active malignancy other than skin cancer, chronic antibiotic use, acute cystitis in past 90 days. | Characteristic (%) Hazard ratio Washington State, USA | | | | Alcohol | Independent predictors of infection included insulin treated diabetes (hazard ratio [HR]_3.4;95%confidence interval [CI]: 1.7 to 7.0) and a lifetime history of urinary tract infection(HR for six or more infections = 6.9; 95% CI: 3.5 to 13.6). Borderline associations included a history of vaginal estrogen cream use in the last month (HR = 1.8; 95% CI: 1.0 to 3.4), a history of kidney stones (HR_1.9; 95% CI: 1.0 to 3.7), and asymptomatic bacteriuria at baseline (HR = 1.8; 95% CI: 0.9 to 3.5).
II-2A | Post void residual bladder volume measured using portable ultrasound device | | | | | Depression | 27% white reported weekly UI vs. 14% black
| 12 month followup done by 87% and 24 month followup by 81% | | | | | Diabetes | (95% Confidence Interval)
| Primary study outcome was sx cystitis | | | | | BMI | Complete sample† 1017 (100)
| | | | | | Parity | Age (years)
| | | | | | Hysterectomy | 55–59 | 32 | 1.0
| | | | | | Oral estrogen use | 60–69 | 42 | 1.3 | (0.8–2.2)
| | | | | | COPD | 70–75 | 26 | 1.6 | (0.9–2.9)
| | | | | | Stroke | Ethnicity
| | | | | | Arthritis | White | 87 | 1.0
| | | | | | Age | Other | 12 | 0.6 | (0.3–1.2)
| | | | | | Race | General health score from SF-36‡
| | | | | | Urinary tract infection | 76–100 | (51) | 1.0
| | | | | | Vaginal estrogen use | 51–75 | (37) | 2.0 | (1.2–3.3)
| | | | | | Race and arthritis were associated with SI and Urge. | 0–50 | (12) | 2.6 | (1.3–4.8)
| | | | | | Current oral estrogen use and arthritis were associated with 1.5 to 2 fold higher odds of SI and Urge | Smoking history
| | | | | | See table 4 | Never | (55) | 1.0
| | | | | | | Former | (39) | 0.9 | (0.5–1.4)
| | | | | | | Current | (6) | 0.1 | (0.02–0.8)
| | | | | | | Diabetes at baseline
| | | | | | | No | (79) | 1.0
| | | | | | | Yes | (21) | 1.9 | (1.1–3.1)
| | | | | | | Diabetes treatment type
| | | | | | | Not diabetic
| | | | | | | | (79) | 1.0
| | | | | | | Diet or pill
| | | | | | | | (17) | 1.2 | (0.7–2.0)
| | | | | | | Insulin | (4) | 4.7 | (2.2–10.3)
| | | | | | | Accidental leakage of urine in last year
| | | | | | | No | (34) | 1.0
| | | | | | | Yes | (66) | 1.6 | (0.9–2.7)
| | | | | | | Type of urinary incontinence in last month
| | | | | | | None | (41) | 1.0
| | | | | | | Stress only
| | | | | | | 174 | (17) | 19 | 0.9 | (0.5–1.8)
| | | | | | | Urge¶ only
| | | | | | | 106 | (10) | 20 | 1.7 | (0.8–3.6)
| | | | | | | Stress and urge
| | | | | | | 324 | (32) | 52 | 1.4 | (0.9–2.4)
| | | | | | | Postvoid residual bladder volume
| | | | | | | <50ml residual
| | | | | | | | (79) | 1.0
| | | | | | | 50–100ml residual
| | | | | | | | (10) | 1.1 | (0.5–2.2)
| | | | | | | >100ml residual
| | | | | | | | (10) | 1.6 | (0.8–3.2)
| | | | | | | History of hysterectomy
| | | | | | | No | (69) | 1.0
| | | | | | | Yes | (31) | 1.2 | (0.8–2.0)
| | | | | | | History of kidney stones
| | | | | | | No | (90) | 11.0
| | | | | | | Yes | (5) | 2.4 | (1.2–4.9)
| | | | | | | History of bladder or urinary surgery
| | | | | | | No | (90) | 1.0
| | | | | | | Yes | (10) | 1.6 | (0.9–3.0)
| | | | | | | Parity (number of full-term pregnancies)
| | | | | | | 0 | (14) | 1.0
| | | | | | | 1–3 | (63) | 1.3 | (0.7–2.5)
| | | | | | | ≥4 | (23) 2.2 | (1.1–4.3)
Johnson, 2004 ^23^ | Men from the Prostate Cancer | 1,433 men RRP | | | | Prostate cancer | Wt % for men with RRP
Long-term cohort, Prospective study of RRP vs. radiotherapy | Outcomes Study diagnosis with primary prostate cancer between Oct 1994–Oct 1995 | 642 men received radiotherapy | | | | RRD | | NHW | AA | Hispanic
II-2B | Residents of LA, King County Washington, states of Connecticut, NM, UT. Between ages of 60–89 years in King County and younger than 90 in others. | RRP group - wt % by race | | | | Radiation therapy | Level of urinary control baseline
| Self questionnaire at 6, 12, 24 and 60 months after diagnosis and medical record review at 12 and 60 months. | | NHW | AA | Hispanic | | Total control | 87.9 | 86.6 | 80.5
| 11,137 men identified in registries; 5,672 randomly selected, letters sent to 4,736 (83.5%) of selected cases. Total of 3,533 men (62.3%) completed 6 and 12 months were included in f/u cohort. | Arthritis | 33.3 | 38.6 | 35.8 | | Occ leakage | 8.8 | 9.5 | 11.2
| 1,433 men had RRP completed 6 months | Diabetes | 11.1 | 29.5 | 17.2 | | Freq leakage | 2.1 | 2 | 6.5
| 1,178 did 24 months (82.2%) | COPD | 7.5 | 6.6 | 5.4 | | P = | .77 | .29
| 1,109 did 60 months (77.4%) | HF | 4.9 | 2.1 | 4.4 | | 6 months
| For radiotherapy - urinary problems not reported | CVA | 2.6 | 2.5 | 3.3 | | total control | 22.7 | 27.6 | 28.9
| Questionnaire also translated into Spanish and interview conducted in Spanish when necessary. | HTN | 37.3 | 54 | 37.5 | | occ leakage | 52.1 | 44.2 | 40.8
| | MI | 7.9 | 4 | 4.2 | | freq | 22.6 | 23.4 | 26.7
| | Age at dx | | | | | p = | 57 | .83
| | <60 | 27.5 | 38.6 | 23.4 | | 12 months
| | 60–64 | 26.8 | 26.1 | 30 | | total control | 33.1 | 38.5 | 37
| | 65–75 | 41.9 | 32.9 | 45.5 | | occ leakage | 50.2 | 51.4 | 46.9
| | >/=75 | 3.8 | 2.4 | 1 | | freq | 15.6 | 9 | 14.9
| | | | | | | p= | .24 | .26
| | | | | | | 24 months
| | | | | | | total control | 38.2 | 41.9 | 35.2
| | | | | | | occ leakage | 50.2 | 45.1 | 53
| | | | | | | freq | 9.8 | 11.1 | 11.3
| | | | | | | p = | .86 | 38
| | | | | | | 60 months
| | | | | | | total control | 30.8 | 49.3 | 32.8
| | | | | | | occ leakage | 53.7 | 39.7 | 47.4
| | | | | | | freq | 14.3 | 10.4 | 18.7
| | | | | | | p = | .01 | .36
Lagergren, 2004 ^24^ | Swedish men and women ≥65 years starting in 3/2001- 3/2004. 12% in SNAC is 65–79 years old, 6% >80 years | Functionally disabled - 37% | | | | Men 3,052 | Prevalence
National, longitudinal, multipurpose study in Sweden (SNAC). | Total pop of SNAC 17,044; baseline 8,627 targeted persons/7,518 sampled | Average PADL - 6.9 | | | | Women 4,465 | Severe UI -
Study consisted of two parts - population part and the care/service part. | 16–25% of SNAC received public care | Severe cognitive impairment (Berger 2–6)- 27% | | | | Total 7,518 | Ordinary homes - 15%
II-2A | Followup every 6 years starting at 66 years | Severe mobility restrictions - 51% | | | | Avg age 85 compared to avg age in Sweden 83 | Special accommodations - 44%
| Combo of interviews and questionnaires | Men 3,052 | | | | Residency | Total 31%
| | Women 4,465
| | Total 7,518
| | Skane, Karlskrona, Kungshomen and Nordanstig, Sweden
| | Average age 85 compared to average age in Sweden 83
Liebling, 2004 ^25^ | 393 UK women with term singleton, cephalic pregnancies who required op delivery at full dilatation between 2/1999–2/2000 from a cohort of 10,106 deliveries | Instrumental; C-section; OR (95% CI) | | | | Mode of delivery | Women in instrumental delivery group were more likely to have UI more occasionally at 6 weeks adjusted OR 7.8 (95% CI, 2.6–23.6) and at 1 year OR 3.1 (95% CI, 1.3–7.6)
Prospective study | Postal questionnaires at 6 weeks and 1 year study conducted at St. Michael's Hospital, Bristol, UK | (184) | (209) | | | Age | Multiparity was a significant risk factor for ‘more than occasional’ UI at 1 year with an adjusted OR of 2.39 (95% CI, .99–5.73)
| Only instrumental vaginal deliveries performed in surgery as the definition of difficult vaginal operative delivery. | Primi: | | | | Parity | At 6 weeks:
| | 78%; 79%;1.09(.67–1.77) | | | | | | Instrum | c-section
| | Age >35: 14%; 9% | | | | | UI | 16.2% | 2.7%
| | Nonwhite: 7%; 5% | | | | | OR 7.8(2.58–23.55)
| | BMI >30: | | | | | At 1 year:
| | 7%; 15%; .44; (.22-.86) | | | | | | 17% | 5.4%
| | 25% attempted with forceps | | | | | OR 3.12(1.27–7.64)
| | 51% were ventouse | | | | | Difficulty holding on to urine
| | 24% both ventouse and forceps rotational delivery attempted in 59% | | | | | | 12.9% | 6.6%
| | | | | | | At 6 weeks: OR 3.59 (1.22–10.54)
| | | | | | | At 1 year: OR 1.90 (.81–4.45)
McGrother, 2004 ^26^ | United Kingdom women AND men | 15% age ≥65 years | | | | Gender | Female to male ratio for storage disorder was 1.5 and was highest with incontinence at 2.6; urgency, 1.6; frequency, 1.4; and nocturia 1.0.
Cross sectional and longitudinal | 162,533 prevalence study and 39,602 incidence study people age ≥40 years | 85.5% White
II - 2B | Response rate 60 and 63% respectively and 79% at followup | 44.9% employed
| Excluded people living in institutional settings | 91.8% good health
| | Mean age: 57
| | 54% women
Neumann, 2004 ^27^ | Study group - 549 Denmark women who had hysterectomy from 1/1/98–12/31/2000 born after 1939 | All women were Caucasian | | | | BMI | BMI associated with de novo significant urge Incontinence and de novo urgency (r=.18 and r = .15 p<.01) - BMI accounted for 1–2% of the variance in these variables
Prospective study | Background group - 144 women who had non-GYN surgery born between 1940-1965 who had lap chole in Denmark. Nulliparae were excluded. | In study group 12% hysterectomy - 33% of these had abdominal, 55% vaginal | | | | | BMI associated with SI before and after hysterectomy (r=.20 and r=.21 p<.01)
II-2A | Questionnaire sent 9–45 months postop
| SI was involuntary leakage during effort, urge as leakage with a sense of urgency, significant UI was defined as involuntary leakage at least once a week, bothersome UI as significant incontinence and use of devices, decreased social ability or having hygienic problem with incontinence. Questionnaires returned by 82% in study group, 76% in background group
Ozerdogan, 2004 ^29^ | 625 women living in Turkey ages 20 and over 4 different cities of Turkey. | Age distribution | | | | Age | UI was associated with advancing age (p <001) UI rate increased from 9.69% in 20–29 to 40% in >70 years.
Cross sectional study, Prospective | Questionnaire and I-QOL; Rare - UI less than once a month Reg - UI more than twice per month | 20–29 - 26.4% | | | | BMI | Hysterectomy was a risk factor for MI and Urge (p<.001)
II-2A | Serious - continuous use of sanitary protection. | 30–39 - 22.6 | | | | Smokers | BMI (OR 12.75, 95% 6.68–24.6) Diabetes (OR 3.55, 95%, 1.44–8.73
| SI and urge defined as usual definitions | 40–49 - 18.7 | | | | Diabetes | Neuro (OR 3.8, 95%, 1.69–8.58 RUTIs (OR 4.73, 95%, 2.52–8.88)
| | 50–59 - 13.4 | | | | | 50% BMI >25, 25% smokers, recurrent UTIs 19%, Diabetes 6.6%, COPD 7.5% Neuro disorders 11.2%
| | 60–69 - 11/7
| | ≥70 – 7.2
| | illiteracy rate 9.4%
| | 1 out of 4 resided in rural area 1 in 5 gave birth at least 4 or more times and most were vaginal deliveries (25%)
Schytt, 2004 ^30^ | Swedish women after childbirth at 593 clinics in Sweden. 5,550 women booked appointments during recruitment time, 4,500 eligible, 3,191 consented, and 3,061 completed 1^st^ questionnaire, 2,762 completed 2^nd^, and 2,563 completed 3^rd^. | Average gestation answering 1^st^ quest - 16 weeks, 2^nd^ - 10 weeks post, 3^rd^ - 1 year and 2 weeks. | | | | Age | Strongest predictor for SI at 1 year in primiparas as well as multi, was UI during pregnancy and PP. Other predictors were obesity and constipation during pregnancy and after birth.
Prospective, longitudinal cohort | Total 2,450 completed all three. Study sample was 2,390 women after exclusion factors also. | Average age at recruit - 29.5 years | | | | Parity | Within the vaginal delivery group, the most important predictors were UI during the third trimester (RR 2.4; CI 95% 2–2.8) and 4–8 weeks PP (RR 2.9, I 95% 2.5–3.3), multiparity (RR 1.3, CI 95% 1.1–1.5), obesity, (RR 1.5 95% 1.1–1.9) and constipation during the third trimester (RR 1.4 (5% CI 1.2–1.6)
II-2A | Selected data from a National Swedish survey investigating physical and psychological assessment of childbirth | Primiparas - 44% | | | | Education
| May and Sept 1999 and January 2000 antepartal visits | Multiparas - 56% | | | | Mode of delivery
| Three questionnaires 1^st^ at baseline, 2^nd^ mailed 6–8 weeks after the birth and 3^rd^ 1 year after birth. Women were asked to recall any symptoms of UI during the pregnancy and post. | 79.2% had vaginal delivery | | | | Smoking
| Excluded miscarriages, non- Swedish speaking, and women from nonparticipating clinics, delivery of twins | 13.4% had C-section
Stenzelius, 2004 ^54^ | Subjects were selected and mailed a questionnaire from a randomized, age-stratified sample of persons ≥75 years living in a southern part of Sweden. Response rate: 52.8% (n=4,277) | Age: 75 and above | | | | Risk Factor | OR | 95% CI
Cross-sectional Adjusted by: Age, Gender, Quality of life, Occupation, Economy, Living condition, Need of help, Satisfaction with children contact, and problems with Communication, Mobility, Elimination, Digestion, Breathing and circulation Psychosocial problems | Data source: Self-reported postal questionnaire | Mean: 83.7 (SD: 5.69) | | | | Sex (0=women, 1=men) | 0.68 | 0.58; 0.81
Other type of pain | Incontinence as a yes to the question, “Have you had problems controlling urine in the last 3 months?” | Gender: Male and Female | | | | Difficult talking | 1.25 | 1.04; 1.54
Level of evidence: III | | Male: 38.4% | | | | Memory problems | 1.7 | 1.42; 2.03
| | Female: 61.6% | | | | Difficulty walking | 1.63 | 1.37; 1.95
| | Race: Not reported | | | | Mobility limitation | 1.23 | 1.02; 1.48
| | Ethnicity: Not reported | | | | Oedema in legs | 1.32 | 1.11; 1.58
| | Residency: Community dwelling and special accommodations residents in Southern Sweden. | | | | Other urinary symptoms | 1.37 | 1.10; 1.71
| | | | | | Diarhoea | 0.66 | 0.50; 0.88
| | | | | | Dizziness | 1.26 | 1.07; 1.50
| | | | | | Protracted coughing | 1.33 | 1.04; 1.69
| | | | | | Fatigue | 1.21 | 1.02; 1.44
Vandoninck, 2004 ^55^ | Dutch women from Urepik (Uro Epi in Europe and Korea) study in the community | Mean age 57 (29–79) | | | | Age | No relationship between mean parity or age and presence of UI; only in oldest category (figure graph in article).
Age stratified | In 1999, a national postal questionnaire survey 1,460 spouses of 1,771 men. | 34% minimal UI | | | | Parity
Prospective cohort for men in the original study. | 1,071 returned- 73% response rate | 12% severe
Mentions sampling weights upon the ratio of # of women in each age group in the sample to # of women in the age group in population. | UI assessed by total score on short UI specific questionnaire - 3 groups - no symptoms score 0–2; minimal 3–6 and severe 7–14. | Mean parity 2.6
?Prospective cohort, no controls | In addition self reported UI calculated conforming to ICS standard definitions. | 13.5% women were childless
| “Do you ever have involuntary urine loss?” | During the past month: %
| QOL also used | How often have you leaked urine?
| | 0 Never | 54.5
| | 1 Not more than once a week | 19.6
| | 2 More than one but less than three times a week | 10.0
| | 3 More than three times a week | 6.0
| | 4 Nearly always | 8.6
| | If you experienced urine loss, how much did you leak?
| | 0 I never leak | 50.2
| | 1 Some drops | 32.2
| | 2 A small stream | 11.4
| | 3 Protection material or clothes soaking wet | 4.9
| | 4 Leaking through pads or clothes | 0.3
| | How often do you use protection material
| | 0 Never | 68.1
| | 1 Occasionally | 21.4
| | 2 Nearly always | 3.9
| | 3 Always | 5.8
| | Did you lose urine on coughing or sneezing?
| | 0 Never | 31.1
| | 1 Occasionally | 45.0
| | 2 Nearly always | 13.5
| | 3 Always | 9.3
Arya, 2001 ^56^ | Subject selection: 315 consecutive primiparous women delivering by forceps (n = 90), vacuum (n = 75), or spontaneously (n = 150). Followup for urinary incontinence was done at 2 weeks, 3 months, and 1 year after delivery. The labor room logs were screened every morning by a research nurse to identify patients who met the eligibility criteria for the study. | Women ≥18years
Prospective | Inclusion criteria: primiparity, vaginal route for delivery, age, gestational age ≥37 weeks, and accessibility by telephone. | USA
Observational | Exclusion criteria: history of urinary incontinence before or during pregnancy, delivery by cesarean section, known diabetes or neurologic disease, and non-English speaking.
II-2 | Definition: Urinary incontinence was defined as the presence of urine loss of any amount that had occurred on at least 2 occasions.
Sherburn, 2001 ^57^ | Subject selection: 2 parts: (1) a cross-sectional phase involving a population-based sample of 1,897 Australian-born women who participated in the baseline interview; (2) a 7-year follow-up phase, assessing a 373 women (premenopausal at 1 year follow-up) from the cross-sectional study. Eligibility for longitudinal study: menstruation in previous 3 months, an intact uterus, at least one ovary, and not currently taking oral contraceptives or HRT. | Women 45–55 years. | | | | Multivariate analysis found that urinary incontinence patients were significantly more likely than those without incontinence to have higher body mass index (odds ratio [OR] 1.50, 95% confidence interval [CI] 1.15, 1.95), have had gynecologic surgery (OR 2.17, 95% CI 1.42, 3.32), report urinary tract infections (OR 4.75, 95% CI 2.28, 9.90), diarrhea or constipation (OR 1.95, 95% CI 1.27, 3.00), and have had three or more children (OR 1.47, 95% CI 1.06, 2.05). | During the 7-year follow-up phase, overall incidence was 35%. Women who experienced a hysterectomy during the followup period had a higher incidence.
Cross-sectional and Longitudinal phases | Response rate: of original cohort, 779 met these criteria and 438 (56%) agreed to be interviewed in the first year of the longitudinal study. | Australia
III
Van Kessel, 2001 ^58^ | Subject selection: The study was conducted at a managed care organization with over 500,000 enrollees. All women who had given birth between 1982 and 1986 and who were continuously enrolled until 1998 were identified with the patient computerized data file. From this cohort, a random sample of women with SUI was selected. 43,288 mother-baby pairs were identified within the computerized database. | Women 22.6–52.9 years | | | | After adjustment factors, the risk for SUI associated with duration of second stage of labor was 1.10 (95% Cl 0.90–1.28; P = .5)
Retrospective | A random, case-controlled sample of 85 cases and 88 controls was identified | USA | | | | There was no significant difference in mode of delivery between cases and controls with one exception; 10.7% of the cases underwent forceps delivery compared with only 1.1% of controls (odds ratio, 10.4; 95% confidence interval, 1.17–93.4; P = .04)
Observational
II-2
Adjustment for factors including mode of delivery, age in years, and duration of enrollment
Larrieu, 2004 ^59^ | Data from the Three-City (3C) study; a collaborative research program from a cohort of 9,294 community-dwellers ≥65 years. | Men and Women ≥65 years | | | | BMI | The univariate analysis showed quite frequent incontinence (20.4%) with prevalence significantly higher in the severely obese (39% vs. ~ 20% in other categories of BMI, P<0.0001).
Cross-sectional | Subjects living at home were randomly sampled from electoral rolls. | 3566 men (39.8%); Mean age: 74.2 y (SD=5.6, not different according to sex)
III | Included 8,966 subjects after excluding 328 subjects with missing BMI. | France
Viktrup, 1992 ^60^ | 305 primiparas interviewed repeatedly about stress incontinence before and during pregnancy and after delivery over 6 month period. | Women 17–41years | | | | Pregnancy | SUI
Observational | Definition: ICS | Denmark | | | | | Before pregnancy: 4%
II-2 | | | | | | | During pregnancy: 32%
| | | | | | | After pregnancy: 7%
Van Kuijk, 2001 ^61^ | Subject selection: All patients with first-time, unilateral hemispheric stroke admitted from August 1994 to August 1997 for a post-acute inpatient rehabilitation program. | Men and Women | | | | | Incidence rates:
Observational (cohort) | Exclusion criteria: non-ischemic stroke, history of previous stroke, evidence of brainstem lesions or bilateral signs on examination, diabetes mellitus, use of anticholinergic medication, history of urinary incontinence, previous urologic surgery, indwelling or intermittent catheterization not regarded as incontinent because of stroke. | Age: | | | | | Overall: 29/1000
II-2 | Definition: Urinary incontinence as any form of involuntary urinary loss. Only urinary incontinence ≤6 months post stroke, considered to be from stroke. | Men: | | | | | Women: 17/1000
| | Mean, 62+-11.5; Range, 32–83yrs | | | | | Men: 39/1000
| | Women: | | | | | The incidence rate of urinary incontinence was 29/1,000 persons per month (95% confidence interval [CI], 18–48/1,000 persons monthly).
| | Mean, 62+ - 12.7 years;
| | Range, 30 – 83 years
| | Netherlands
Schmidbauer, 2001 ^62^ | Subject selection: Analysis of ~2,500 participants in a health screening project in the area of Vienna, using Bristol LUTS incontinence questionnaire and (a) medical history; (b) a physical investigation; (c) sociodemographic parameters (smoking, eating and drinking habits), and (d) urine and blood study including 14 parameters. The parameters collected during this health investigation were correlated to the presence of urinary incontinence to identify potential risk factors for urinary incontinence. | Age: | | | | Parity showed a strong correlation to UI. | In women with no childbirth 16.5% reported on UI, this percentage increased to 29.9% (one child), 29.6% (two children), 33.3% (three children), and 57.7% (four or more children).
Cross-sectional | Definition: UI was defined as any involuntary loss of urine within the past four weeks. | Men (49.7+-13.6 years), | | | | 26.3% reported episodes of urinary incontinence in the past 4 weeks. Other factors, age (r = 0.22), BMI (r = 0.20), urgency (r = 0.16), feeling of incomplete bladder emptying (r = 0.21), previous urogynecological surgery and fasting blood glucose correlated significantly to UI., 5% of men were incontinent, age (r = 0.12), urgency (r = 0.16), nocturia (r = 0.16), feeling of incomplete emptying (r = 0.16), reduced uroflow (r = 0.18) and previous prostatectomy (r = 0.11) correlated to the presence of UI. Smoking habits and education level revealed no association in either sex.
III | | Women (48.6+-13 years)
| | Austria
Hu, 2004 ^63^ | Subject selection: women at Group Health Cooperative of Puget Sound (GHC), a staffmodel health maintenance organization with approximately 450,000 members in western Washington State. Study subjects with a recent diagnosis of acute UTI. Women were then randomly selected from GHC enrollment files to serve as control subjects, matched to cases by date of birth (within 2 years). | Women aged 55–75 years | | | | Acute UTI | Case subjects more likely than controls to report episodes of incontinence >x/month (ageadjusted OR, 1.74; 95% CI, 1.44–2.10) and incontinence with typical quantities greater than a few drops (age-adjusted OR, 1.71; 95% CI, 1.38–2.11).
Observational | | USA | | | | | Infrequent incontinence and incontinence of only a few drops were not associated with increased odds of UTI.
II-2
Bradley, 2005 ^64^ | Women with intact uterus enrolled in the Women's Health Initiative Hormone Therapy trial. | Age: Mean: 68.2 (SD: 5.6) | | | | Risk factor | UI | OR
Cross-sectional | Response rate: 88% (n=297) | Gender: Female | | | | Age | Difficulty emptying bladder | 3.3
Adjusted by: Age, BMI, Parity, Smoking, Alcohol use, Coffee, Exercise, Education, Prior surgery, Angina, Hypothyroidism, Hypertension, Asthma, Pelvic floor symptoms | Data source: Self-reported written validated questionnaire | Race: Not reported | | | | | | (0.9, 12.2)
Level of evidence: III | Incontinence as, “Urinary leaking at least once in the last 3 months.” | Ethnicity: Not reported | | | | | Feeling of incomplete bladder emptying | 3.4
| | Residency: Midwest, USA | | | | | | (1.3, 9.2)
| | | | | | | Weak urinary stream | 6.4
| | | | | | | | (2.0, 20.0)
| | | | | | | Intermittent urinary stream | 4.0
| | | | | | | | (1.6, 10.4)
| | | | | | | Vaginal or perineal splinting to defecate | 2.2
| | | | | | | | (1.0, 4.8)
| | | | | | | Feeling of incomplete bowel movements | 2.7
| | | | | | | | (1.2, 5.9)
| | | | | | Body mass index | Urgency | 1.8
| | | | | | | | (0.8, 4.0)
| | | | | | | Urge urinary leaking | 2.2
| | | | | | | | (1.0, 4.8)
| | | | | | | Intermittent urinary stream | 0.8
| | | | | | | | (0.3, 1.9)
| | | | | | Exercise (>weekly) | Urinary urgency | 0.6
| | | | | | | | (0.4, 1.0)
| | | | | | | Fecal urgency | 0.3
| | | | | | | | (0.2, 0.8)
| | | | | | Coffee drinking | Difficulty emptying bladder | 8.6
| | | | | | | | (1.4, 55.0)
| | | | | | | Weak urinary stream | 5.3
| | | | | | | | (1.5, 19.0)
| | | | | | Smoking | Pelvic heaviness | 5.4
| | | | | | | | (1.0, 30.0)
| | | | | | | Fecal urgency | 2.9
| | | | | | | | (0.7, 11.7)
O'Donnell, 2005 ^65^ | Subject selection: In 2001, a 13 item questionnaire was mailed to a representative sample of 29,500 community-dwelling women to determine the prevalence, type and treatment behavior of women with UI. Within 2 months of the initial survey a more detailed selfcompletion questionnaire was mailed to a randomly selected sub-sample of 2,953 women identified as having UI from the initial survey. Follow-up included questions on general health status, quality of life and help-seeking behavior, characteristics of UI, and women's attitudes to health care in general and UI specifically. | Women ≥18 years with UI | | | | UI and women's attitudes were found to be associated with help-seeking after adjusting for age, UI duration and frequency, and ‘bother’ of UI; factors traditionally associated with help-seeking. | Initial survey:
Observational | Response rate: 58% in the initial and 535 in the second. | France, Germany, Spain and the UK. | | | | After adjustment for these factors, willingness to take long-term medication and having spoken to others about UI were found to be strong predictors of help-seeking in all four countries. | SUI
II-2 | Definition: UI was defined as any leakage or involuntary loss of urine, conforming to the standards recommended by the ICS. For the purpose of this study this definition was restricted to an incidence during the last 30 days. | | | | | | France: 30%
| | | | | | | Germany: 40%
| | | | | | | Spain: 39%
| | | | | | | UK: 41%
| | | | | | | Total: 37%
| | | | | | | UUI
| | | | | | | France: 27%
| | | | | | | Germany: 16%
| | | | | | | Spain: 20%
| | | | | | | UK: 16%
| | | | | | | Total: 20%
| | | | | | | MUI
| | | | | | | France: 34%
| | | | | | | Germany: 37%
| | | | | | | Spain: 26%
| | | | | | | UK: 34%
| | | | | | | Total: 33%
| | | | | | | Followup survey:
| | | | | | | SUI
| | | | | | | France: 37%
| | | | | | | Germany: 46%
| | | | | | | Spain: 44%
| | | | | | | UK: 44%
| | | | | | | Total: 43%
| | | | | | | UUI
| | | | | | | France: 9%
| | | | | | | Germany: 9%
| | | | | | | Spain: 14%
| | | | | | | UK: 10%
| | | | | | | Total: 10%
| | | | | | | MUI
| | | | | | | France: 50%
| | | | | | | Germany: 42%
| | | | | | | Spain: 34%
| | | | | | | UK: 42%
| | | | | | | Total: 42%
Samuelsson,2000 ^66^ | Subjects were selected from women aged 20–59 who were invited in for their gynecological health examination. The exam is conducted every third year for women in Sweden. | Age: 20–59 | | | | Age years | Crude Odds ratios
Cross-sectional | Response rate: 76% (n=487) | Gender: Female | | | | 20–29 years | 1
Adjusted by:, Age Parity, Weight Smoking Type of delivery Co-morbidity Hormonal use Surgical history Pelvic floor muscle strength Genital prolapse | Data source: Self-reported postal questionnaire | Race: Not reported | | | | 30–39 years | 4.18 | 2.04; 8.57
Level of evidence: III | Incontinence was defined as a positive response to, “Do you suffer from involuntary loss of urine?” | Ethnicity: Not reported | | | | 40–49 years | 7.21 | 3.47; 15.00
| | Residency: Urban area in Mid-Sweden | | | | 50–59 years | 9.52 | 4.82; 18.82
| | | | | | Parity
| | | | | | 0 deliveries | 1
| | | | | | 1 delivery | 3.92 | 2.14; 7.20
| | | | | | 2 deliveries | 5.24 | 3.01; 9.10
| | | | | | >3 deliveries | 8.59 | 4.53; 16.27
| | | | | | Smoking habits
| | | | | | Never smoked | 1
| | | | | | Former smoker | 1.28 | 0.78; 2.09
| | | | | | Current smoker | 1.78 | 1.12; 2.86
| | | | | | Weight
| | | | | | 45–58 kg | 1 | 0.54; 1.41
| | | | | | 59–70 kg | 0.87 | 0.65; 1.96
| | | | | | 71–105 kg | 1.13 | 2.67; 8.93
| | | | | | ERT use
| | | | | | No | 1
| | | | | | Yes | 4.89
| | | | | | Type of delivery | Prevalence, %
| | | | | | Vaginal
| | | | | | Section | 42.2
| | | | | | Episiotomy | 30.8
| | | | | | No episiotomy
| | | | | | Episiotomy | 45.2
| | | | | | Maximum birth weight (g) <3199 | 35.7
| | | | | | 3200 – 3924 | 35.5
| | | | | | >3925 | 44.7
| | | | | | Type of genital prolapse | 43.8
| | | | | | Loss of urethrovesical crease | 53.2
| | | | | | Rectocele | 55.3
| | | | | | Cystocele | 58.1
| | | | | | Uterine prolapse | 72
| | | | | | Degree of prolapse
| | | | | | None | 18.7
| | | | | | Not to introitus | 47.9
| | | | | | To introitus | 62.5
| | | | | | # of prolapse components
| | | | | | None | 18.7
| | | | | | One | 31
| | | | | | Two | 59.6
| | | | | | Three | 66.7
| | | | | | Four | 100
| | | | | | Age (years) | Adjusted odds ratios
| | | | | | 20–29 | 1
| | | | | | 30–39 | 2.31 | 1.18; 4.51
| | | | | | 40–49 | 2.2 | 1.07; 4.52
| | | | | | 50–59 | 3.47 | 1.25; 4.90
| | | | | | Parity
| | | | | | 0 deliveries | 1
| | | | | | 1 delivery | 1.38 | 0.68; 2.81
| | | | | | 2 deliveries | 1.84 | 0.94; 3.59
| | | | | | 3 deliveries or more | 2.71 | 1.27; 5.77
| | | | | | Smoking habits
| | | | | | Never smoked | 1 | reference
| | | | | | Former smoker | 1.42 | 0.81; 2.57
| | | | | | Current smoker | 1.86 | 1.08; 3.22
| | | | | | Pelvic floor muscle strength (scores)
| | | | | | 4 | 1 | reference
| | | | | | 3 | 1.51 | 0.87; 2.62
| | | | | | 2 | 2.56 | 1.33; 4.93
| | | | | | 1 | 3.44 | 0.51; 23.09
| | | | | | Presence of cystocele and/or absence of urethrovesical crease
| | | | | | No | 1 | »
| | | | | | Yes | 2.49 | 1.48; 4.18
| | | | | | ERT use
| | | | | | No | 1
| | | | | | Yes | 2.91 | 1.44; 5.89
Adelmann, 2004 ^50^ | Community UI prevalence sample of 910 persons to a 1998-1999 survey enrolled in a Medicaid managed health plan | Characteristics of community and nursing home N=910 | | | | Race | Prevalence of UI in community sample
Prospective cohort | Seven county Minneapolis-St. Paul metro area | | Community | NH (%) | | Age | | Ever/current | Past week
| Age ≥65 | Women | 82.1% | 79.2 | | Gender | UI (%)
| Random sample of 910 persons enrolled in Medicaid health plan. Of this the n= 378 that were eligible due to UI. Sample was further limited to persons based on at least one claim for a doctor's visit and medical chart could be located. n=236 | Men | 17.9 | 20.8 | | | Total | 41.6 | 23
| Nursing home abstraction sample was randomly drawn from Medicaid persons for a total of 480 persons. | Age | | | | | Women | 45 | 25.5
| Interviews face to face in residence. Response rate 59%, cooperation rate 90%. | 65–74 | 50% | 14 | | | Men | 25.8 | 11.7
| Abstraction of medical record at clinics also. | 75–84 | 34.9 | 34.2 | | | Age
| Definition: ever/current UI measured by a yes response to questions about trouble holding urine or leaking urine | 85+ | 15.1 | 51.9 | | | 65–74 | 34.1 | 17.6
| | Mean | 75.9 | 84.5 | | | 75–84 | 45. | 26.2
| | Race | | | | | 85+ | 58.1 | 33.8
| | White | 69.4 | 93.8 | | | Race
| | Black | 14.5 | 4.6 | | | White | 45 | 25.5
| | Other | 16.2 | 1.7 | | | Black | 39.8 | 20.3
| | | | | | | Other | 30.1 | 16.1
| | | | | | | Subgroup report by race and age Race among women (self report)
| | | | | | | | p<.003 | p<.016
| | | | | | | White | 49 | 28.7
| | | | | | | Black | 43 | 22.4
| | | | | | | Other | 31.9 | 16.4
| | | | | | | | p,.001 | p<.001
| | | | | | | 65–74 | 37.4 | 20.4
| | | | | | | 75–84 | 47.7 | 27.6
| | | | | | | 85+ | 62.1 | 36.3
| | | | | | | Age among Whites
| | | | | | | | p<.001 | p<.001
| | | | | | | 65–74 | 35.3 | 19.5
| | | | | | | 75–84 | 49.8 | 27.7
| | | | | | | 85+ | 59.1 | 35.7
| | | | | | | Age among Blacks
| | | | | | | | p<.037 | p<.021
| | | | | | | 65–74 | 34.1 | 14.6
| | | | | | | 75–84 | 46.2 | 28.2
| | | | | | | 85+ | 71.4 | 57.1
| | | | | | | Age among White women
| | | | | | | | p<.001 | p<.005
| | | | | | | 65–74 | 39.1 | 22.9
| | | | | | | 75–84 | 53.1 | 30.3
| | | | | | | 85+ | 62.3 | 37.7
| | | | | | | Age among Black women
| | | | | | | | p<.044 | p<.050
| | | | | | | 65–74 | 36.4 | 16.7
| | | | | | | 75–84 | 50 | 29.4
| | | | | | | 85+ | 71.4 | 42.9
| | | | | | | Medically detected UI in community and nursing home samples
| | | | | | | | Community | Nursing Home
| | | | | | | | Past 18 months | Past 12 months
| | | | | | | Total | 22.3% | 77.2%
| | | | | | | Gender | p=.278 | p=.174
| | | | | | | Age in years | p.868 | p<.001
| | | | | | | 65–74 | 61.2%
| | | | | | | 75–84 | 75%
| | | | | | | 85+ | 82.7%
| | | | | | | race also insignificant p
| | | | | | | Prevalence of medically treated UI
| | | | | | | | Community | Nursing Home
| | | | | | | | Past 18 months | Past 12 months
| | | | | | | any type | 64.8% | 6.5%
| | | | | | | SI | 38.9% | 3%
| | | | | | | Urge | 9.3 | 0
| | | | | | | Other | 5.6 | 2.4
| | | | | | | Mixed | 11.1 | 0.3
Andersson, 2004 ^10^ | Swedish population, both men and women ages 18–79 years (Orebro county) in March 2000 | 7,680 females | | | | Age | Prevalence reported by age and gender for weekly
Population based study | Questionnaire mailed to home comprising 12 questions on UI as a supplement to a large public health survey on health and general living. Mailed to 15,360 randomly selected residents out of 274,000 populations in this county. | 7,680 males | | | | Gender | Women (men)
II-3 | Response rate 64.5% | | | | | | Women (men)
| | | | | | | 18–35 - 3 (1); 35–49 - 10 (2); 50–64 - 13 (3); 65–79 - 21(8).
| | | | | | | Total for weekly
| | | | | | | Women - 11% Men 3%
| | | | | | | SI total for women 77%, men 13% 18–34 - 59(18); 35–49 - 83(13); 50–64 - 83(11); 65–79 - 71(13)
| | | | | | | Urge Incontinence for women 46%; men 45%
| | | | | | | 18–34 - 42(18); 35–49 - 38(37); 50–64 - 48(43); 65–79 - 53(59)
| Swedish population 3/2000, Life and Health questionnaire sent to 70,000 residents randomly selected. In Orebro, pop of 274,000, one of the five counties that participated in above study, a special section on UI was given to a sample of 15,360 residents | 7,680 females | | | | Gender | Women more affected than men
| Postal questionnaire with 12 questions on UI | 7,680 males | | | | Age | Proportion of people with UI increased markedly with age
| Sample of 15,360 residents ages 18–79 years of Orebro, Sweden; Response rate was 64.5% | Age | categories | | | | | At least 1/week | At any time
| Used definitions from ICS | 18–36 | 53.9% | | | | Women | 11% | 27%
| Stats on weights and calibration and found results were the same | 35–51 | 60.3 | | | | 18–34 | 3 | 10
| | 50–66 | 69.6 | | | | 35–49 | 10 | 26
| | 65–81 | 72.2 | | | | 50–64 | 13 | 37
| | | | | | | 65–79 | 21 | 39
| | | | | | | Men | 3% | 10%
| | | | | | | 18–34 | 1 | 3
| | | | | | | 35–49 | 2 | 6
| | | | | | | 50–64 | 3 | 13
| | | | | | | 65–79 | 8 | 21
| | | | | | | | SI | Urge
| | | | | | | Women | 77 | 46
| | | | | | | Men | 13 | 45
| | | | | | | Duration of UI years
| | | | | | | <1 | 24%
| | | | | | | 1–6 | 51
| | | | | | | 6–11 | 14
| | | | | | | >10 | 11
Bogner, 2004 ^11^ | ECA (Epi Catchment Area) program was used to sample from Baltimore to include 3,481 persons selected from East Baltimore for this study. | Mean age of study sample was 67.2 | | | | Age | 22% Whites reported UI
Population based longitudinal survey | Community dwelling adults who were initially living in East Baltimore in 1981. | 64% were women | | | | Gender | 13% of Blacks reported UI
II-2B | Out of 3,481 persons, 1,920 were contacted (73% of original cohort). | 72.3% White; mean age 68.2 ± 11 | | | | Functional status | 19.8% reported UI during the year preceding the interview
| Study sample included 822 persons aged ≥50 who completed info on UI. | 27.7% AA - mean age 64.5 ± 10 | | | | Cognitive status | | White (540) | Black (207)
| After exclusions for missing data, 747 were the final sample. | | White | Black | | Chronic medical conditions-diabetes, heart trouble, stroke, arthritis or cancer | UI | 22.4% | 13%
| African Americans and Whites aged ≥50 at followup interview performed 1993- 1996 | Diabetes | 14.3 | 16.9 | | Race | No information on SI, Urge Incon.
| Age ≥65 were over sampled | Heart trouble | 27.4 | 26.6 | | | Association between UI and Psychological Distress
| GHQ used and self report on UI | Arthritis | 51.1 | 56.5 | | | Crude | Adjusted OR (95% CI)
| UI = “Have you ever had any difficulty in controlling your water, losing your urine or having trouble getting to the bathroom on time?” If any uncontrolled urine loss was reported within the 12 months before the interview, persons were classified as having UI. | Stroke | 8.2 | 7.3 | | | White
| | Cancer | 14.4 | 6.3 | | | 1.28 (.76–2.14) | 1.07 (.62–1.84)
| | MME | 27.6±2.6 | 25.6±3.6 | | | Black
| | ADL impaired | 1.9% | 3.9% | | | 4.22 (1.72–10.39) | 5.6 (1.88–16.67)
Corcos, 2004 ^12^ | Canadian population ≥35 | 48.2% men; mean age 52 | | | | Gender | Wet OAB markedly higher in both men and women over age 75 years
Prospective cohort | Stratified by census of metro area and by gender. 7,487 persons were sample base. 53.7% response rate. | 51.8% women; mean age 50.9 | | | | Age | No correlation observed between age and prevalence of mixed OAB in women whereas linear relationship was noted in men
No control mentioned | 3,249 interviews from Montreal, Toronto, Vancouver, and Edmonton were final sample | 82.4% younger than 65 and
| Investigators developed standardized questionnaire to ascertain OAB and SUI and impact on quality of life. | 17.6% older
| Computer assisted telephone interviews conducted in 2 steps: an initial questionnaire evaluate presence of OAB followed by detailed questionnaire completing the assessment.
Dallosso, 2004 ^13^ | Part of the Leicestershire MRC | Baseline data compared to those who provided FFQ data. | | | | BMI | | Incidence at 1 year followup
Prospective longitudinal study | Incontinence Study. This study focused on women living in the community in UK ages ≥40. | Median age 57 vs. 61. Rating of health poorer in baseline after adjusting for age (OR: 1.66; 95% CI 1.51–1.82). More longterm health problems in baseline (OR 1.14; 95% CI, 1.05–1.25). No difference in reporting SUI (OR: 1.02; CI 95%, .92–1.13) | | | | Fat intake | | Total N | SUI cases %
II=2B | A random sample of 20,244 women drawn, 12,565 returned the questionnaire (65% response rate). | | | | | Vitamin usage | 40–49 | 1242 | 9.3
| FFQ sent to 10,852 of above sample. 7,460 completed it (response rate 65%) | | | | | Cholesterol and other dietary factors | 50–59 | 1272 | 7.2
| 1^st^ postal questionnaire mailed Oct 1998 and completed by 7,046 women. | | | | | Age | 60–69 | 1108 | 7.6
| 2^nd^ postal questionnaire mailed Oct 1999 and completed by 6,424 women (91% response rate). | | | | | | 70–79 | 756 | 8.3
| Excluded women living in residential or nursing homes | | | | | | 80y + | 214 | 12.6
| Excluded those of South Asian origin who make up 5.3% of Leicestershire pop over 40 years. | | | | | | only significant p abstracted - others in article not significant
| Used ICS definitions | | | | | | Total fat
| | | | | | | OR (95% CI) Q2-Q5 1.38 (.89–2.13); 1.35 (.88–2.08); 1.27 (.83–1.94); 2.02 (1.33–3.05) p=.02
| | | | | | | Sat fat
| | | | | | | 1.08 (.69–1.69); 1.46(.96–2.22); 1.08 (.7–1.67); 2.02 (1.35–3.03) p = .001
| | | | | | | Carbs
| | | | | | | .95 (.65–1.38); .68 (.46–1.01); .59 (.39-.9); .73 (.49–1.08) p=.05
| | | | | | | Cholesterol
| | | | | | | 1.09 (.70–1.69); 1.24 (.81–1.9); 1.34 (.88–2.04); 2.09 (1.4–3.14) p=.003 after adjusting for BMI, fat unchanged but carbs were no longer sig p=.07
| | | | | | | 3 vitamins associated with SUI
| | | | | | | Vit B12
| | | | | | | Zinc
| | | | | | | Retinol was marginal
| | | | | | | After adjusting for BMI, association with B12 remained + while zinc was no longer sig.
de Tayrac, 2004 ^31^ | French women - study population 717 who had Dargent and Rudigoz technique | Vaginal hyst. | Control group | | | Age | Prevalence (as stated in article)
Case control, retrospective study | 449 did not respond 365 (50.9%) returned questionnaires 51 excluded leaving 314 women | Age | | | | Parity | | Vag hyster % | Control %
II-3 | 117 patients who had a vaginal hysterectomy for menorrhagia from Jan 1991 to Dec 2001 control group of 116 patients who had conservative treatment | 51.4 | 50.9 | | | Menopausal status | Freq day>8 | 19.7% | 16.4%
| 197 had hysterectomy for pelvic pain and 117 for menorrhagia | Parity | | | | Smoking | Noc: day > 1 | 5.1 | 6.9
| self report questionnaire | 2.1 | 2.2 | | | Volume of drink | Urgency | 62.4 | 54.3
| | Menopause | | | | Did not report incidence by each of these | Qmo | 36.8 | 30.2
| | 43.5% | 47.4% | | | | Qwk | 19.7 | 12.1
| | Smoking | | | | | Qday | 6 | 12.1
| | 17.9% | 17.2% | | | | UI | 39.3 | 33.6
| | Drink >2 L/day | | | | | Use of pads | 15.4 | 12.9
| | 7.7% | 9.5% | | | | Urge Inc | 20.5 | 13.8
| | History of uro sxs | | | | | Qmonth | 12 | 7.8
| | 0 | 0 | | | | Qweek | 4.3 | 5.2
| | | | | | | Qday | 4.3 | 0.9
| | | | | | | SI | 36.7 | 31.9
| | | | | | | Qmonth | 18.8 | 16.4
| | | | | | | Qweek | 12.8 | 8.6
| | | | | | | Qday | 4.3 | 3.5
| | | | | | | Age <60 | VH | Control
| | | | | | | UI | 41.8% | 33.7
| | | | | | | Urge Incon | 21.8 | 12.5
| | | | | | | SI | 40 | 33.7
| | | | | | | Age >60
| | | | | | | UI | 28.6 | 41.7
| | | | | | | Urge Incon | 14.3 | 25
| | | | | | | SI | 28.6 | 33.3
Deliveliotis, 2004 ^15^ | 283 Greek men from 441 patients enrolled. | Mean ages | | | | Types of surgery | RRP; TURP; pretreatment; post treatment
Prospective cohort | 105/142 patients treated with RRP for prostate cancer | 67.4 | range 55–75 | group 1 | | | Urinary fun
II-2A | 98/151patients treated with TURP for BPH | 70.3 | range 58–74 | group 2 | | | 85.1; 80.2; .121; 71.2; 87.3; .005
| 80/148 healthy men as control completed surveys | 72.4 | range 62–82 | control | | | Urinary bother
| used AUA Sx Index, UCLA Prostate Cancer Index; Rand 36-Item Health Survey and BMSFI translated into Greek | HRQOL post treatment | | | | | 85.1; 70.6; .021; 65.1; 80.2; .003
| Patient outcomes 2 years post treatment compared to pretreatment status at 2 weeks prior to treatment | RRP | TURP | Control | | | AUA SI
| investigators felt poor returns due to length of questionnaires and the number of them | Physical functioning | | | | | 11.1; 8.6; .812; 24.2; 8.2; .001
| | 81.5 | 78.1 | 82.3 | | | UI every day
| | | | | | | 2%; 9%; .002; 12%; 2.78%; .002
| | | | | | | RRP had trend towards worse urinary function 2 years after surgery but difference not significant. Urinary bother deteriorated.
| | | | | | | UI in control group was 5.78%
Fritel, 2004 ^52^ | French women from hospital database of 1^st^ birth women who had not previously delivered fetus >22 weeks | Table I. Analysis of the differences among responders, women not reached and nonresponders concerning potential risk factors for stress urinary incontinence (SUI) Risk factor Responders Not reached Nonresponders p | | | | Age at 1^st^ delivery | Table III. Risk factors for SUI 4 years after the first delivery
Retrospective cohort | 307/669 primiparous women who delivered in 1996 in vertex position between 37–41 weeks (274 had moved and 88 did not respond) 45.9% response rate. Excluding the women who did not receive the questionnaire (274), response rate was 77.7% | Age at delivery | | | | BMI | SUI
II-2C | Mailed questionnaire sent 4 weeks after delivery and asked about SUI before, during, and after pregnancy - “Do you have loss of urine during physical exertion, cough or sneeze?” | 29.3 [4.4]; 28.2 [4.4]; 28.9 [4.7] 0.01 | | | | Birth weight | Risk factor: Yes (n=89) No (n=218) p
| UI categorized slight, mode or severe using Sandvik Index | BMI (kg/m2): 21.3 [2.9]; 21.1 [2.9]; 21.3 [3.2] 0.62 | | | | Duration of labor | Age at delivery >30 years: 53.9 (48); 36.7 (80); 0.005
| | Birth weight (g): 3240 [384]; 3253 [400]; 3241 [430] 0.92 | | | | Duration of second stage | BMI >27 kg/m2: 2.2 (2); 4.6 (10); 0.34
| | Labor (hours) 6.2 [2.3]; 6.5 [2.5]; 6.6 [2.3] 0.21 | | | | Mode of delivery | Birth weight ≥4000g 2.2 (2); 1.4 (3); 0.58
| | Active 2nd stage (minutes): 11.1 [7.5];10.6 [7.9]; 10.9 [7.9] 0.69 | | | | 3^rd^ degree tear at first delivery | Labor ≥8 hours: 41.6 (37); 21.1 (46); 0.0002
| | C- section: 10.1 (31);17.5 (48);17.0 (15) 0.03 | | | | Second delivery since 1996 | Active 2nd stage ≥20 minutes: 16.9 (15); 19.3 (42); 0.62
| | Forceps: 36.2 (111);31.3 (86); 44.3 (39) 0.08 | | | | Urinary leakage before 1^st^ pregnancy | C section: 6.7 (6); 11.5 (25); 0.21
| | Third-degree tear: 1.3 (4); 1.1 (3);1.1 (1) 0.97 | | | | Urinary leakage during 1^st^ pregnancy | Forceps: 38.2 (34); 35.3 (77); 0.63
| | | | | | | 3^rd^ degree tear: 2.2 (2); 0.9 (2); 0.35
| | | | | | | Leak before pregnancy: 16.1; 0.9 <0.0001
| | | | | | | Leak during pregnancy: 40.2; 15.3 <0.0001
| | | | | | | 2^nd^ delivery: 69.6 (53); 61.0 (133); 0.81
| | | | | | | Table IV. Risk factors for stress urinary incontinence 4 years after the first delivery
| | | | | | | Risk factor Odds ratio 95% CI p
| | | | | | | Leakage before the 1st pregnancy 18.7 3.6–96.4 0.0005
| | | | | | | Leakage during the 1st pregnancy 2.5 1.3–4.8 0.005
| | | | | | | Age at the 1st delivery: >30 years: 2.4 1.4–4.2 0.002
| | | | | | | Labor ≥8 hours 3.1 1.7–5.7 0.0002
| | | | | | | Cesarean at the 1st delivery: 0.3 0.1–0.9 0.04
| | | | | | | Adjusted odds ratios estimated by logistic regression analysis
| | | | | | | According to multiple logistic regression analysis, the independent risk factors were urine leakage before the first pregnancy [odds ratio (OR) 18.7; 95% confidence interval (CI) 3.6–96.4], urine leakage during the first pregnancy (OR 2.5; 95% CI 1.3–4.8), duration of first labor ≥8 hours (OR 3.1; 95% CI 1.7–5.7), mother's age >30 years at the first delivery (OR 2.4; 95% CI 1.4–4.2) and cesarean section at the first delivery (OR 0.3; 95% CI 0.1–0.9).
| | | | | | | Table III. Risk factors for SUI 4 years after the first delivery
| | | | | | | SUI
| | | | | | | Risk factor: Yes (n=89); No (n=218) p
| | | | | | | Age at delivery >30 years: 53.9 (48); 36.7 (80) 0.005
| | | | | | | BMI >27 kg/m2: 2.2 (2); 4.6 (10) 0.34
| | | | | | | Birth weight ≥4000g: 2.2 (2); 1.4 (3) 0.58
| | | | | | | Labor ≥8 hours: 41.6 (37); 21.1 (46) 0.0002
| | | | | | | Active 2nd stage ≥20 minutes: 16.9 (15); 19.3 (42) 0.62
| | | | | | | C section: 6.7 (6); 11.5 (25) 0.21
| | | | | | | Forceps: 38.2 (34); 35.3 (77) 0.63
| | | | | | | 3^rd^ degree tear: 2.2 (2); 0.9 (2) 0.35
| | | | | | | Leak before pregnancy: 16.1; 0.9 <0.0001
| | | | | | | Leak during pregnancy: 40.2; 15.3 <0.0001
| | | | | | | 2^nd^ delivery: 69.6 (53); 61.0 (133) 0.81
| | | | | | | Table IV. Risk factors for stress urinary incontinence 4 years after the first delivery
| | | | | | | Risk factor Odds ratio 95% CI p
| | | | | | | Leakage before 1st pregnancy: 18.7 3.6–96.4 0.0005
| | | | | | | Leakage during 1st pregnancy: 2.5 1.3–4.8 0.005
| | | | | | | Age at 1st delivery >30 years: 2.4 1.4–4.2 0.002
| | | | | | | Labor ≥8 hours 3.1 1.7–5.7 0.0002
| | | | | | | Cesarean at 1st delivery: 0.3 0.1–0.9 0.04
| | | | | | | Adjusted odds ratios estimated by logistic regression analysis
Grodstein, 2004 ^16^ | Nurse Health Study from 1996-2000 females | Cohort of 39,436 women ages 50–75 | | | | Age | 5,060 incident cases of occasional UI
Prospective cohort | Questionnaire mailed in 1996 to 39,436 women post menopausal women who had no leaking of urine and were followed for 4 years | Mean age 61 for current HRT use; 64 for never used | | | | BMI | 2,495 incident cases of frequent UI
II-2A | Incident cases of occasion UI were defined as leaking 1–3 times per month; frequent were at least once per week | BMI for never used HRT was 27 | | | | Smokers | Average incidence rate of 3.2% per year and 1.6% per year respectively
Confounded for stroke and physical limitations and results were the same in both analysis | Excluded premenopausal women or users of estrogen creams, or reported leaking in 1996 | Current use BMI was 47 and past use for BMI was 47 | | | | Recurrent UTI | 50–55 years yearly incontinence was 3% in those who never took HRT
| | Hormone Use Post Menopause | | | | Diabetes | 56–60 - 3.5
| | Never | Current | Past | | COPD | 61–65 - 3.8
| | Caucasian | | | | Neurological disorders | 66–70 - 4.3
| | 98 | 97 | 98 | | Parity | 71–75 years - 5.3%
| | African American | | | | HRT
| | 1 | 1 | 1
| | Hispanic
| | 0 | 1 | 0
| | Asian
| | 1 | 1 | 1
| | Smokers @ 45% all
| | Hysterectomy
| | 6 | 47 | 40
Groutz, 2004 ^53^ | 363 consecutive primiparae followed for 1 year | Vaginal; Obstructed; Elective C-sec | | | | Age | SUI significant in heavier women - 67±10kg vs. 59±9 kg p=.001 and increase in prevalence during pregnancy 67% vs. 27% p=.003.
Prospective cohort elective C-section without trial of labor vs. vaginal delivery vs. Csection due to obstructed labor | SUI before pregnancy excluded | Delivery; labo; c-sec | | | | Maternal age | Duration of 1^st^, 2^nd,^ and active second stages of labor were stat longer (p<.05) in women who had PP SUI compared to those without P SUI (376 vs. 287min, 121 vs.. 103 min; 61 vs. 43min)
II-2A (if controls are considered types of deliveries) | Non-singleton deliveries, instrumentalassisted vaginal deliveries excluded | Age: 28±4; 32.5±5.3; 31.7±5.2 | | | | Weight | Older maternal age (36 years vs. 32 years), heavier maternal weight (71kg vs. 63kg) and prevalence of SUI during pregnancy was noted among incontinent vs. continent women
| 145 spontaneous vaginal delivery | Weight: 60±9; 62.5±11.6; 63±13 | | | | Height
| 100 C-section following obstructed labor with mean cervical dilation of 8.7 ± 1.6cm | Height: 164+/-6/6; 162±5.6; 164±6.7 | | | | Mode of delivery
| 118 elective C section | Gestation age: 39.7; 40.2; 38.8
| Interviewed one year PP | Birth weight: 3,251; 3,450; 3,260
| SUI - involuntary leakage with cough, sneeze, etc | Israeli women delivered at Tel Aviv Sourasky Medical Center
| Regular UI as defined by involuntary excretion or leakage of urine in inappropriate places or times twice or more a month, regardless of quantity loss
Hagglund, 2004 ^17^ | Swedish women all 145 incontinent and 193 continent women ages 22–50 in year 2000. Same group of women had participated in earlier study 1995 on prevalence. | | | | | Age | Women continent at baseline incidence
4 year followup cohort study | Response rate 73% 248/338 | | | | | | 22–31 | 13%
II-2A | Among the 248 responders as followup, 118 reported UI and 130 reported being continent. | | | | | | 31–41 | 16
| Changes in type of UI measured using DIS | | | | | | 41–50 | 18
| “Do you have problem with involuntary loss of urine?” | | | | | | Women incontinent at baseline
| | | | | | | 22–31 | 33
| | | | | | | 31–41 | 18
| | | | | | | 41–51 | 13
Haltbakk, 2004 ^18^ | 480 Norwegian men at St. Olavs Hospital, Trondheim Norway. Tentative diagnosis of BPH made on 612 patients and from this pool, sample analyzed was 480 (78%). | Mean age of patients was 67 years, SD 10.6 years; median 69 years range 39–91 years | | | | Age | 3/4 of men experienced sleeping problems during previous months and 31% had experienced sleeping problems
Prospective cohort no control mentioned ? historical control | ICS LUTS questionnaire (ICS-BPH) between 1997-2000. IPSS, SPI and SISI used also. | 15% mild symptoms | | | | | Issues related to altered lifestyle were recognized by 7–90% of men and 47% reported they would be mostly dissatisfied if their current urinary symptoms persisted for rest of life.
| UI defined as any involuntary leakage of urine. | 54% moderate symptoms | | | | | Incontinent group - 64% had sx ≤5 years 22% for 5–10 years 6% for >/=10 years remaining 8% did not indicate
| | 31% severe symptoms
| | Mean age in incontinent group was 68 years
Holroyd-Leduc, 2004 ^19^ | Community dwelling in U.S. | Mean age ≤SD = 77 (range 69–103) | | | | Age | UI and outcomes adjusted OR (95%CI)
Population based | 6,506 of 7,447 subjects ages ≥70 in the Asset and Health Dynamics Among the Oldest Old study who had complete info on continence status were baseline - outcomes 3 groups- 5,872 nursing home, 5,521 ADL decline and 5,509 IADL decline as outcomes | 63% female | | | | Sex | Death: 10.9% .90 (.67–1.21)
Prospective cohort | Subjects interviewed in 1993 and 1995 | 86% White | | | | SES | Nursing home: 4.4% 1.33 (.86–2.04)
Confounders - sex, age, socioeconomic status, race, smoking, alcohol, BMI, sensory impairment, comorbid disease, depression, cognitive function and baseline dependency. | Blacks, Hispanics, and Florida residents were over sampled | Median number of baseline comorbid medical conditions was 2 | | | | Race | ADL decline: 13.6% 1.24 (.92–1.68)
II-2A | Overall response rate was 80% | 10% received help with 1 or more ADLs and 23% were receiving help in 1 or more IADLS at baseline | | | | Smoking/alcohol | IADL decline: 21.2% 1.31 (1.05–1.63)
| UI measured “next question might not be easy to talk about, but it is very important for research on health & aging, during the last 12 months, have you lost any amount of urine beyond your control?” | Patients with UI had more comorbidities (p=.001), higher rate of visual impairment (35% vs. 22.4% p <.001) and hearing impairment (39.7% vs. 30.5% p<.001) | | | | BMI | More functionally impaired at baseline
| | | | | | Sensory impairment
| | | | | | Comorbidity
| | | | | | Cognitive scores
| | | | | | Depression
| | | | | | ADL
| | | | | | IADL
Hunskaar, 2004 ^20^ | Postal survey mailed to 29,500 households in 4 countries - France, Germany, UK and Spain age ≥18 years | Mean age | | | | Age | No new cases reported
Cross national study, Prospective | 58.1% response rate women with UI included in analysis was 5976 (35% of study population) | France - 44.8 | | | | Ethnic background | Only prevalence reported by country
No control group | Definitions used by ICS; symptoms in last 30 days and in last 7 days | Germany - 59
| | UK - 45
| | Spain - 64
| | All - 58
Jackson, 2004 ^22^ | 1,017 post menopausal U.S. women ages 55–75 enrolled in HMO and followed for 2 years (1998-2002) inclusion criteria were no natural menstrual cycle in past 12 months. Exclusion: oral estrogen or vaginal estrogen, residential nursing care, restriction to wheel chair, dementia or severe psych disorder, indwelling catheter or intermittent urinary catheter, end stage renal disease requiring dialysis, active malignancy other than skin cancer, chronic antibiotic use, acute cystitis in past 90 days. | Frequency of Exposures at Enrollment and Univariate Risk of Symptomatic Urinary Tract Infection | | | | Smoking | Incidence of UTI was .07 per person per year.
Population based | Post void residual bladder volume measured using portable ultrasound device | Characteristic (%) Hazard ratio Washington State, USA | | | | Alcohol | Independent predictors of infection included insulin treated diabetes (hazard ratio [HR]=3.4;95%confidence interval [CI]: 1.7 to 7.0) and a lifetime history of urinary tract infection(HR for six or more infections = 6.9; 95% CI: 3.5 to 13.6). Borderline associations included a history of vaginal estrogen cream use in the last month (HR = 1.8; 95% CI: 1.0 to 3.4), a history of kidney stones (HR=1.9; 95% CI: 1.0 to 3.7), and asymptomatic bacteriuria at baseline (HR = 1.8; 95% CI: 0.9 to 3.5).
Prospective cohort; also randomly selected from HMO diabetes registry | 12 month followup done by 87% and 24 month followup by 81% | | | | | Depression | 27% white reported weekly UI vs. 14% black
II-2A | Primary study outcome was sx cystitis | | | | | Diabetes | (95% Confidence Interval)
| | | | | | BMI | Complete sample† 1017 (100)
| | | | | | Parity | Age (years)
| | | | | | Hysterectomy | 55–59 | 32 | 1.0
| | | | | | Oral estrogen use | 60–69 | 42 | 1.3 | (0.8–2.2)
| | | | | | COPD | 70–75 | 26 | 1.6 | (0.9–2.9)
| | | | | | Stroke | Ethnicity
| | | | | | Arthritis | White | 87 | 1.0
| | | | | | Age | Other | 12 | 0.6 | (0.3–1.2)
| | | | | | Race | General health score from SF-36‡
| | | | | | Urinary tract infection | 76–100 | (51) | 1.0
| | | | | | Vaginal estrogen use | 51–75 | (37) | 2.0 | (1.2–3.3)
| | | | | | Race and arthritis were associated with SI and Urge. | 0–50 | (12) | 2.6 | (1.3–4.8)
| | | | | | Current oral estrogen use and arthritis were associated with 1.5 to 2 fold higher odds of SI and Urge | Smoking history
| | | | | | See table 4 | Never | (55) | 1.0
| | | | | | | Former | (39) | 0.9 | (0.5–1.4)
| | | | | | | Current | (6) | 0.1 | (0.02–0.8)
| | | | | | | Diabetes at baseline
| | | | | | | No | (79) | 1.0
| | | | | | | Yes | (21) | 1.9 | (1.1–3.1)
| | | | | | | Diabetes treatment type
| | | | | | | Not diabetic | (79) | 1.0
| | | | | | | Diet or pill | (17) | 1.2 | (0.7–2.0)
| | | | | | | Insulin | (4) | 4.7 | (2.2–10.3)
| | | | | | | Accidental leakage of urine in last yr
| | | | | | | No | (34) | 1.0
| | | | | | | Yes | (66) | 1.6 | (0.9–2.7)
| | | | | | | Type of urinary incontinence in last month
| | | | | | | None | (41) | 1.0
| | | | | | | Stress only
| | | | | | | 174 | (17) | 19 | 0.9 | (0.5–1.8)
| | | | | | | Urge¶ only
| | | | | | | 106 | (10) | 20 | 1.7 | (0.8–3.6)
| | | | | | | Stress and urge
| | | | | | | 324 | (32) | 52 | 1.4 | (0.9–2.4)
| | | | | | | Postvoid residual bladder volume
| | | | | | | <50ml residual
| | | | | | | | (79) | 1.0
| | | | | | | 50–100ml residual
| | | | | | | | (10) | 1.1 | (0.5–2.2)
| | | | | | | >100ml residual
| | | | | | | | (10) | 1.6 | (0.8–3.2)
| | | | | | | History of hysterectomy
| | | | | | | No | (69) | 1.0
| | | | | | | Yes | (31) | 1.2 | (0.8–2.0)
| | | | | | | History of kidney stones
| | | | | | | No | (90) | 11.0
| | | | | | | Yes | (5) | 2.4 | (1.2–4.9)
| | | | | | | History of bladder or urinary surgery
| | | | | | | No | (90) | 1.0
| | | | | | | Yes | (10) | 1.6 | (0.9–3.0)
| | | | | | | Parity (number of full-term pregnancies)
| | | | | | | 0 | (14) | 1.0
| | | | | | | 1–3 | (63) | 1.3 | (0.7–2.5)
| | | | | | | ≥4 | (23) | 2.2 | (1.1–4.3)
Johnson, 2004 ^23^ | Men from the Prostate Cancer Outcomes Study diagnosis with primary prostate cancer between Oct 1994–Oct 1995 | 1,433 men RRP | | | | Prostate cancer | Wt % for men with RRP
Long-term cohort, Prospective study of RRP vs. radiotherapy | Residents of LA, King County Washington, states of Connecticut, NM, UT. Between ages of 60–89 years in King County and younger than 90 in others. | 642 men received radiotherapy | | | | RRD | | NHW | AA | Hispanic
II-2B | Self questionnaire at 6, 12, 24 and 60 months after diagnosis and medical record review at 12 and 60 months. 11,137 men identified in registries; 5,672 randomly selected, letters sent to 4,736 (83.5%) of selected cases. Total of 3,533 men (62.3%) completed 6 and 12 months were included in f/u cohort. | RRP group - wt % by race | | | | Radiation therapy | Level of urinary control baseline
| 1,433 men had RRP completed 6 months | | NHW | AA | Hispanic | | Total control | 87.9 | 86.6 | 80.5
| 1,178 did 24 months (82.2%) | Arthritis | 33.3 | 38.6 | 35.8 | | Occ leakage | 8.8 | 9.5 | 11.2
| 1,109 did 60 months (77.4%) | Diabetes | 11.1 | 29.5 | 17.2 | | Freq leakage | 2.1 | 2 | 6.5
| For radiotherapy - urinary problems not reported | COPD | 7.5 | 6.6 | 5.4 | | P = | .77 | .29
| Questionnaire also translated into Spanish and interview conducted in Spanish when necessary. | HF | 4.9 | 2.1 | 4.4 | | 6 months total control | 22.7 | 27.6 | 28.9
| | CVA | 2.6 | 2.5 | 3.3 | | occ leakage | 52.1 | 44.2 | 40.8
| | HTN | 37.3 | 54 | 37.5 | | freq | 22.6 | 23.4 | 26.7
| | MI | 7.9 | 4 | 4.2 | | p = | 57 | .83
| | Age at dx | | | | | 12 months total control | 33.1 | 38.5 | 37
| | <60 | 27.5 | 38.6 | 23.4 | | occ leakage | 50.2 | 51.4 | 46.9
| | 60–64 | 26.8 | 26.1 | 30 | | freq | 15.6 | 9 | 14.9
| | 65–75 | 41.9 | 32.9 | 45.5 | | p= | .24 | .26
| | >/=75 | 3.8 | 2.4 | 1 | | 24 months total control | 38.2 | 41.9 | 35.2
| | | | | | | occ leakage | 50.2 | 45.1 | 53
| | | | | | | freq | 9.8 | 11.1 | 11.3
| | | | | | | p = | .86 | 38
| | | | | | | 60 months total control | 30.8 | 49.3 | 32.8
| | | | | | | occ leakage | 53.7 | 39.7 | 47.4
| | | | | | | freq | 14.3 | 10.4 | 18.7
| | | | | | | p = | .01 | .36
Lagergren, 2004 ^24^ | Swedish men and women from Skane, Karlskrona, Kungshomen and Nordanstig ages ≥65 starting in 2001- March 2004, 12% in SNAC is 65–79 years old, 6% >80 years | Functionally disabled - 37% | | | | Men 3052 | Prevalence
National, longitudinal, multipurpose study in Sweden (SNAC). Study consisted of two parts - population part and the care/service part. | Total pop of SNAC 17,044; baseline 8,627 targeted persons/7,518 sampled | Average PADL - 6.9 | | | | Women 4465 | Severe UI -
II-2A | 16–25% of SNAC received public care | Severe cognitive impairment (Berger 2–6)- 27% | | | | Total 7518 | Ordinary homes - 15%
| Followup every 6 years starting at 66 years | Severe mobility restrictions - 51% | | | | Avg age 85 compared to avg age in Sweden 83 | Special accommodations - 44%
| Combo of interviews and questionnaires | Men 3,052 | | | | Residency | Total 31%
| | Women 4,465
| | Total 7,518
| | Average age 85 compared to average age in Sweden 83
McGrother, 2004 ^26^ | United Kingdom women AND men | 15% age ≥65 years | | | | Gender | Female to male ratio for storage disorder was 1.5 and was highest with incontinence at 2.6; urgency, 1.6; frequency, 1.4; and nocturia 1.0.
Cross sectional and longitudinal | 162,533 prevalence study and 39,602 incidence study people age ≥40 years | 85.5% White
II - 2B | Response rate 60 and 63% respectively and 79% at followup | 44.9% employed
| Excluded people living in institutional settings | 91.8% good health
| | Mean age: 57
| | 54% women
Neumann, 2004 ^27^ | Study group - 549 Denmark women who had hysterectomy from 1/1/98–12/31/2000 born after 1939 | All women were Caucasian | | | | BMI | BMI associated with de novo significant urge Incontinence and de novo urgency (r=.18 and r = .15 p<.01) - BMI accounted for 1–2% of the variance in these variables
Prospective study | Background group - 144 women who had non-GYN surgery born between 1940-1965 who had lap chole in Denmark. Nulliparae were excluded. | In study group 12% hysterectomy - 33% of these had abdominal, 55% vaginal | | | | | BMI associated with SI before and after hysterectomy (r=.20 and r=.21 p<.01)
II-2A | Questionnaire sent 9–45 months postop
| SI was involuntary leakage during effort, urge as leakage with a sense of urgency, significant UI was defined as involuntary leakage at least once a week, bothersome UI as significant incontinence and use of devices, decreased social ability or having hygienic problem with incontinence. Questionnaires returned by 82% in study group, 76% in background group
Ozerdogan, 2004 ^29^ | 625 women living in Turkey ages 20 and over 4 different cities of Turkey. | Age distribution | | | | Age | UI was associated with advancing age (p <001) UI rate increased from 9.69% in 20–29 to 40% in >70 years.
Cross sectional study, Prospective | Questionnaire and I-QOL; Rare - UI less than once a month Reg - UI more than twice per month Serious - continuous use of sanitary protection. | 20–29 - 26.4% | | | | BMI | Hysterectomy was a risk factor for MI and Urge (p<.001)
II-2A | SI and urge defined as usual definitions | 30–39 - 22.6 | | | | Smokers | BMI (OR 12.75, 95% 6.68–24.6)
| | 40–49 - 18.7 | | | | Diabetes | Diabetes (OR 3.55, 95%, 1.44–8.73
| | 50–59 - 13.4 | | | | | Neuro (OR 3.8, 95%, 1.69–8.58
| | 60–69 - 11/7 | | | | | RUTIs (OR 4.73, 95%, 2.52–8.88)
| | ≥70 - 7.2 | | | | | 50% BMI >25, 25% smokers, recurrent UTIs 19%, Diabetes 6.6%, COPD 7.5% Neuro disorders 11.2%
| | illiteracy rate 9.4%
| | 1 out of 4 resided in rural area
| | 1 in 5 gave birth at least 4 or more times and most were vaginal deliveries (25%)
Schytt, 2004 ^30^ | Swedish women after childbirth at 593 clinics in Sweden. 5,550 women booked appointments during recruitment time, 4,500 eligible, 3,191 consented, and 3,061 completed 1^st^ questionnaire, 2,762 completed 2^nd^, and 2,563 completed 3^rd^. Total 2,450 completed all three. Study sample was 2,390 women after exclusion factors also. | Average gestation answering 1^st^ quest - 16 weeks, 2^nd^ - 10 weeks post, 3^rd^ - 1 year and 2 weeks. | | | | Age | Strongest predictor for SI at 1 year in primiparas as well as multi, was UI during pregnancy and PP. Other predictors were obesity and constipation during pregnancy and after birth.
Prospective, longitudinal cohort | Selected data from a National Swedish survey investigating physical and psychological assessment of childbirth May and Sept 1999 and January 2000 antepartal visits | Average age at recruitment - 29.5 years | | | | Parity | Within the vaginal delivery group, the most important predictors were UI during the third trimester (RR 2.4; CI 95% 2–2.8) and 4–8 weeks PP (RR 2.9, I 95% 2.5–3.3), multiparity (RR 1.3, CI 95% 1.1–1.5), obesity, (RR 1.5 95% 1.1–1.9) and constipation during the third trimester (RR 1.4 (5% CI 1.2–1.6)
II-2A | Three questionnaires 1^st^ at baseline, 2^nd^ mailed 6–8 weeks after the birth and 3^rd^ 1 year after birth. Women were asked to recall any symptoms of UI during the pregnancy and post. | Primiparas - 44% | | | | Education
| Excluded miscarriages, non-Swedish speaking, and women from nonparticipating clinics, delivery of twins | Multiparas - 56% | | | | Mode of delivery
| | 79.2% had vaginal delivery | | | | Smoking
| | 13.4% had C-section
Stenzelius, 2004 ^54^ | Subjects were selected and mailed a questionnaire from a randomized, agestratified sample of persons ≥75 years living in a southern part of Sweden. Response rate: 52.8% (n=4,277) | Age: 75 and above | | | | Risk Factor | OR | 95% CI
Cross-sectional Adjusted by: Age, Gender, Quality of life, Occupation, Economy, Living condition, Need of help, Satisfaction with children contact, and problems with Communication, Mobility, Elimination, Digestion, Breathing and circulation | Data source: Self-reported postal questionnaire | Mean: 83.7 (SD: 5.69) | | | | Sex (0=women, 1=man) | 0.68 | 0.58–0.81
Psychosocial problems | Incontinence as a yes to the question, “Have you had problems controlling urine in the last 3 months?” | Gender: Male and Female | | | | Difficult talking | 1.25 | 1.04–1.54
Other type of pain | | Male: 38.4% | | | | Memory problems | 1.7 | 1.42–2.03
Level of evidence: III | | Female: 61.6% | | | | Difficulty walking | 1.63 | 1.37–1.95
| | Race: Not reported | | | | Mobility limitation | 1.23 | 1.02–1.48
| | Ethnicity: Not reported | | | | Oedema in legs | 1.32 | 1.11–1.58
| | Residency: Community dwelling and special accommodations residents in Southern Sweden. | | | | Other urinary symptoms | 1.37 | 1.10–1.71
| | | | | | Diarrhea | 0.66 | 0.50–0.88
| | | | | | Dizziness | 1.26 | 1.07–1.50
| | | | | | Protracted coughing | 1.33 | 1.04–1.69
| | | | | | Fatigue | 1.21 | 1.02–1.44
Vandoninck, 2004 ^55^ | Dutch women from Urepik (Uro Epi in Europe and Korea)study in the community | Mean age 57 (29–79) | | | | Age | No relationship between mean parity or age and presence of UI; only in oldest category (figure graph in article).
Age stratified | In 1999, a national postal questionnaire survey | 34% minimal UI | | | | Parity
Prospective cohort for men in the original study. | 1,460 spouses of 1,771 men. 1,071 returned- 73% response rate | 12% severe
Mentions sampling weights upon the ratio of # of women in each age group in the sample to # of women in the age group in population. | UI assessed by total score on short UI specific questionnaire - 3 groups - no symptoms score 0–2; minimal 3–6 and severe 7–14. In addition self reported UI calculated conforming to ICS standard definitions. | Mean parity 2.6
Prospective cohort, no controls | “Do you ever have involuntary urine loss?” | 13.5% women were childless
| QOL also used | During the past month: | %
| | How often have you leaked urine?
| | 0 Never | 54.5
| | 1 Not more than once/wk | 19.6
| | 2 More than one but less than three times a week 10.0
| | 3 More than 3 times/week | 6.0
| | 4 Nearly always | 8.6
| | If you experienced urine loss, how much did you leak?
| | 0 I never leak | 50.2
| | 1 Some drops | 32.2
| | 2 A small stream | 11.4
| | 3 Protection material or clothes soaking wet | 4.9
| | 4 Leaking through pads or clothes | 0.3
| | How often do you use protection material
| | 0 Never | 68.1
| | 1 Occasionally | 21.4
| | 2 Nearly always | 3.9
| | 3 Always | 5.8
| | Did you lose urine on coughing or sneezing?
| | 0 Never | 31.1
| | 1 Occasionally | 45.0
| | 2 Nearly always | 13.5
| | 3 Always | 9.3
Arya, 2001 ^56^ | Subject selection: 315 consecutive primiparous women delivering by forceps (n = 90), vacuum (n = 75), or spontaneously (n = 150). Follow-up for UI was done at 2 weeks, 3 months, and 1 year after delivery. The labor room logs were screened every morning by a research nurse to identify patients who met the eligibility criteria for the study. Inclusion criteria: primiparity, vaginal route for delivery, age, gestational age ≥37 weeks, and accessibility by telephone. Exclusion criteria: history of urinary incontinence before or during pregnancy, delivery by cesarean section, known diabetes or neurologic disease, and non- English speaking. | Women ≥18 years
Prospective | Definition: Urinary incontinence was defined as the presence of urine loss of any amount that had occurred on at least 2 occasions. | USA
Observational
II-2
Sherburn, 2001 ^57^ | Subject selection: 2 parts: (1) a crosssectional phase involving a populationbased sample of 1,897 Australian-born women who participated in the baseline interview; (2) a 7-year follow-up phase, assessing a 373 women (premenopausal at 1 year follow-up) from the cross-sectional study. Eligibility for longitudinal study: menstruation in previous 3 months, an intact uterus, at least one ovary, and not currently taking oral contraceptives or HRT. | Women 45–55 years. | | | | Multivariate analysis found that urinary incontinence patients were significantly more likely than those without incontinence to have higher body mass index (odds ratio [OR] 1.50, 95% confidence interval [CI] 1.15, 1.95), have had gynecologic surgery (OR 2.17, 95% CI 1.42, 3.32), report urinary tract infections (OR 4.75, 95% CI 2.28, 9.90), diarrhea or constipation (OR 1.95, 95% CI 1.27, 3.00), and have had three or more children (OR 1.47, 95% CI 1.06, 2.05). | During the 7-year followup phase, overall incidence was 35%. Women who experienced a hysterectomy during the followup period had a higher incidence.
Cross-sectional and Longitudinal phases | Response rate: of original cohort, 779 met these criteria and 438 (56%) agreed to be interviewed in the first year of the longitudinal study. | Australia
III
Van Kessel, 2001 ^58^ | Subject selection: The study was conducted at a managed care organization with over 500,000 enrollees. All women who had given birth between 1982 and 1986 and who were continuously enrolled until 1998 were identified with the patient computerized data file. From this cohort, a random sample of women with SUI was selected. 43,288 mother-baby pairs were identified within the computerized database. | Women 22.6–52.9 years | | | | After adjustment factors, the risk for SUI associated with duration of second stage of labor was 1.10 (95% Cl 0.90–1.28; p = .5)
Retrospective | A random, case-controlled sample of 85 cases and 88 controls was identified | USA | | | | There was no significant difference in mode of delivery between cases and controls with one exception; 10.7% of the cases underwent forceps delivery compared with only 1.1% of controls (odds ratio, 10.4; 95% CI, 1.17–93.4; p = .04)
Observational
II-2
Adjustment for factors including mode of delivery, age in years, and duration of enrollment
Larrieu, 2004 ^59^ | Data from the Three-City (3C) study; a collaborative research program from a cohort of 9,294 community-dwellers ≥65 years. Subjects living at home were randomly sampled from electoral rolls. Included 8,966 subjects after excluding 328 subjects with missing BMI. | Men and Women ≥65 years 3566 men (39.8%); Mean age: 74.2 y (SD=5.6, not different according to sex) | | | | BMI | The univariate analysis showed quite frequent incontinence (20.4%) with prevalence significantly higher in the severely obese (39% vs. ~ 20% in other categories of BMI, P<0.0001).
Cross-sectional | | France
III
Viktrup, 1992 ^60^ | 305 primiparas interviewed repeatedly about stress incontinence before and during pregnancy and after delivery over 6 month period. | Women 17–41years | | | | Pregnancy | SUI
Observational | Definition: ICS | Denmark | | | | | Before pregnancy: 4%
II-2 | | | | | | | During pregnancy: 32%
| | | | | | | After pregnancy: 7%
Van Kuijk, 2001 ^61^ | Subject selection: All patients with firsttime, unilateral hemispheric stroke admitted from August 1994 to August 1997 for a post-acute inpatient rehabilitation program. | Men and Women | | | | | Incidence rates:
Observational (cohort) | Exclusion criteria: non-ischemic stroke, history of previous stroke, evidence of brainstem lesions or bilateral signs on examination, diabetes mellitus, use of anticholinergic medication, history of urinary incontinence, previous urologic surgery, indwelling or intermittent catheterization not regarded as incontinent because of stroke. | Age: | | | | | Overall: 29/1000
II-2 | Definition: Urinary incontinence as any form of involuntary urinary loss. Only urinary incontinence ≤6 months post stroke, considered to be from stroke. | Men: | | | | | Women: 17/1000
| | Mean, 62+-11.5; | | | | | Men: 39/1000
| | Range, 32–83 years | | | | | The incidence rate of urinary incontinence was 29/1,000 persons per month (95% confidence interval [CI], 18–48/1,000 persons monthly).
| | Women:
| | Mean, 62+-12.7 years;
| | Range, 30–83 years
| | Netherlands
Schmidbauer, 2001 ^62^ | Subject selection: Analysis of ~2,500 participants in a health screening project in the area of Vienna, using Bristol LUTS incontinence questionnaire and (a) medical history; (b) a physical investigation; (c) socio-demographic parameters (smoking, eating and drinking habits), and (d) urine and blood study including 14 parameters. The parameters collected during this health investigation were correlated to the presence of urinary incontinence to identify potential risk factors for urinary incontinence. | Age: | | | | Parity showed a strong correlation to UI. | In women with no childbirth 16.5% reported on UI, this percentage increased to 29.9% (one child), 29.6% (two children), 33.3% (three children), and 57.7% (four or more children).
Cross-sectional | Definition: UI was defined as any involuntary loss of urine within the past four weeks. | Men (49.7+-13.6yrs), | | | | 26.3% reported episodes of urinary incontinence in the past 4 weeks. Other factors, age (r = 0.22), BMI (r = 0.20), urgency (r = 0.16), feeling of incomplete bladder emptying (r = 0.21), previous urogynecological surgery and fasting blood glucose correlated significantly to UI., 5% of men were incontinent, age (r = 0.12), urgency (r = 0.16), nocturia (r = 0.16), feeling of incomplete emptying (r = 0.16), reduced uroflow (r = 0.18) and previous prostatectomy (r = 0.11) correlated to the presence of UI. Smoking habits and education level revealed no association in either sex.
III | | Women(48.6+-13yrs)
| | Austria
Hu, 2004 ^63^ | Subject selection: women at Group Health Cooperative of Puget Sound (GHC), a staff-model health maintenance organization with approximately 450,000 members in western Washington State. Study subjects with a recent diagnosis of acute UTI. Women were then randomly selected from GHC enrollment files to serve as control subjects, matched to cases by date of birth (within 2 years). | Women aged 55–75 years | | | | Acute UTI | Case subjects more likely than controls to report episodes of incontinence >x/month (ageadjusted OR, 1.74; 95% CI, 1.44–2.10) and incontinence with typical quantities greater than a few drops (age-adjusted OR, 1.71; 95% CI, 1.38–2.11). Infrequent incontinence and incontinence of only a few drops were not associated with increased odds of UTI.
Observational | | USA
II-2
O'Donnell, 2005 ^65^ | Subject selection: In 2001, a 13 item questionnaire was mailed to a representative sample of 29,500 community-dwelling women to determine the prevalence, type and treatment behavior of women with UI. Within 2 months of the initial survey a more detailed self-completion questionnaire was mailed to a randomly selected sub-sample of 2,953 women identified as having UI from the initial survey. Follow-up included questions on general health status, quality of life and help-seeking behavior, characteristics of UI, and women's attitudes to health care in general and UI specifically. | Women ≥18 years with UI | | | | UI and women's attitudes were found to be associated with help-seeking after adjusting for age, UI duration and frequency, and ‘bother’ of UI; factors traditionally associated with help-seeking. | Initial survey:
Observational | Response rate: 58% in the initial and 535 in the second. | France, Germany, Spain and the UK. | | | | After adjustment for these factors, willingness to take long-term medication and having spoken to others about UI were found to be strong predictors of helpseeking in all four countries. | SUI
II-2 | Definition: UI was defined as any leakage or involuntary loss of urine, conforming to the standards recommended by the ICS. For the purpose of this study this definition was restricted to an incidence during the last 30 days. | | | | | | France: 30%
| | | | | | | Germany: 40%
| | | | | | | Spain: 39%
| | | | | | | UK: 41%
| | | | | | | Total: 37%
| | | | | | | UUI
| | | | | | | France: 27%
| | | | | | | Germany: 16%
| | | | | | | Spain: 20%
| | | | | | | UK: 16%
| | | | | | | Total: 20%
| | | | | | | MUI
| | | | | | | France: 34%
| | | | | | | Germany: 37%
| | | | | | | Spain: 26%
| | | | | | | UK: 34%
| | | | | | | Total: 33%
| | | | | | | Followup survey:
| | | | | | | SUI
| | | | | | | France: 37%
| | | | | | | Germany: 46%
| | | | | | | Spain: 44%
| | | | | | | UK: 44%
| | | | | | | Total: 43%
| | | | | | | UUI
| | | | | | | France: 9%
| | | | | | | Germany: 9%
| | | | | | | Spain: 14%
| | | | | | | UK: 10%
| | | | | | | Total: 10%
| | | | | | | MUI
| | | | | | | France: 50%
| | | | | | | Germany: 42%
| | | | | | | Spain: 34%
| | | | | | | UK: 42%
| | | | | | | Total: 42%
Samuelsson, ^66^ | Subjects were selected from women aged 20–59 who were invited in for their gynecological health examination. The exam is conducted every third year for women in Sweden. | Age: 20–59 | | | | Age years | Crude Odds ratios
Cross-sectional | Response rate: 76% (n=487) | Gender: Female | | | | 20–29 years | 1
Adjusted by:, Age Parity, Weight | Data source: Self-reported postal questionnaire | Race: Not reported | | | | 30–39 years | 4.18 | 2.04–8.57
Smoking | Incontinence was defined as a positive response to, “Do you suffer from involuntary loss of urine?” | Ethnicity: Not reported | | | | 40–49 years | 7.21 | 3.47–15.00
Type of delivery | | Residency: Urban area in Mid-Sweden | | | | 50–59 years | 9.52 | 4.82–18.82
Co-morbidity | | | | | | Parity
Hormonal use | | | | | | 0 deliveries | 1
Surgical history | | | | | | 1 delivery | 3.92 | 2.14–7.20
Pelvic floor muscle strength | | | | | | 2 deliveries | 5.24 | 3.01–9.10
Genital prolapse | | | | | | >3 deliveries | 8.59 | 4.53–16.27
Level of evidence: III | | | | | | Smoking habits
| | | | | | Never smoked | 1
| | | | | | Former smoker | 1.28 | 0.78–2.09
| | | | | | Current smoker | 1.78 | 1.12–2.86
| | | | | | Weight
| | | | | | 45–58 kg | 1 | 0.54–1.41
| | | | | | 59–70 kg | 0.87 | 0.65–1.96
| | | | | | 71–105 kg | 1.13 | 2.67–8.93
| | | | | | ERT use
| | | | | | No | 1
| | | | | | Yes | 4.89
| | | | | | | Prevalance, %
| | | | | | Type of delivery
| | | | | | Vaginal | 42.2
| | | | | | Section | 30.8
| | | | | | Episiotomy
| | | | | | No episiotomy | 45.2
| | | | | | Episiotomy | 35.7
| | | | | | Maximum birth weight (g)
| | | | | | <3199 | 35.5
| | | | | | 3200 – 3924 | 44.7
| | | | | | >3925 | 43.8
| | | | | | Type of genital prolapse
| | | | | | Loss of urethrovesical crease | 53.2
| | | | | | Rectocele | 55.3
| | | | | | Cystocele | 58.1
| | | | | | Uterine prolapse | 72
| | | | | | Degree of prolapse
| | | | | | None | 18.7
| | | | | | Not to introitus | 47.9
| | | | | | To introitus | 62.5
| | | | | | Number of prolapse components
| | | | | | None | 18.7
| | | | | | One | 31
| | | | | | Two | 59.6
| | | | | | Three | 66.7
| | | | | | Four | 100
| | | | | | Age (years) | Adjusted odds ratios
| | | | | | 20–29 | 1
| | | | | | 30–39 | 2.31 | 1.18; 4.51
| | | | | | 40–49 | 2.2 | 1.07; 4.52
| | | | | | 50–59 | 3.47 | 1.25; 4.90
| | | | | | Parity
| | | | | | 0 deliveries | 1
| | | | | | 1 delivery | 1.38 | 0.68; 2.81
| | | | | | 2 deliveries | 1.84 | 0.94; 3.59
| | | | | | 3 deliveries or more | 2.71 | 1.27; 5.77
| | | | | | Smoking habits
| | | | | | Never smoked | 1 | »
| | | | | | Former smoker | 1.42 | 0.81; 2.57
| | | | | | Current smoker | 1.86 | 1.08; 3.22
| | | | | | PFMS
| | | | | | 4 | 1 | »
| | | | | | 3 | 1.51 | 0.87; 2.62
| | | | | | 2 | 2.56 | 1.33; 4.93
| | | | | | 1 | 3.44 | 0.51; 23.09
| | | | | | Presence of cystocele and/or absence of urethrovesical crease
| | | | | | No | 1 | »
| | | | | | Yes | 2.49 | 1.48; 4.18
| | | | | | ERT use
| | | | | | No | 1
| | | | | | Yes | 2.91 | 1.44; 5.89

Multiple logistic regression of ‘long term’ UI and delivery mode history ^67^

Variable | Incontinence Total | N | % | Odds ratio | (95% CI) | P
Delivery mode history
All other histories | 2,707 | 1263 | (46.7) | 1.0 | Reference
Only caesarean section(s) | 435 | 141 | (32.4) | 0.50 | 0.40–0.63 | 0.001
Any forceps | 1,029 | 480 | (46.6) | 0.96 | 0.83–1.11 | 0.567
Maternal age at first birth
<25 | 1,432 | 568 | (39.7) | 1.0 | Reference | 0.001
25–29 | 1,697 | 766 | (45.1) | 1.34 | 1.15–1.55 | 0.001
30–34 | 835 | 427 | (51.1) | 1.88 | 1.57–2.25 | 0.001
>35 | 207 | 123 | (59.4) | 2.98 | 2.18–4.07 | 0.001
Number of births
One | 528 | 202 | (38.3) | 1.0 | Reference | 0.001
Two | 2,202 | 993 | (45.1) | 1.30 | 1.07–1.59 | 0.001
Three | 1,025 | 490 | (47.8) | 1.61 | 1.29–2.02 | 0.001
Four or more | 416 | 199 | (47.8) | 1.73 | 1.31–2.27 | 0.001
Number of women | 5 4171
Number symptomatic | 5 1884
Symptoms are yes at 6 years

Supplemental Evidence Table: Association between risk factors and incidence of UI in adults in the community and long-term care settings Odds of UI according to potential risk factors, 2006 ^68^

Variable | Occasional Incontinence* OR (95% CI) | | Frequent Incontinence* OR (95% CI) | | Severe Incontinence* OR (95% CI)
Age (years)
<40 | 2,270 | Reference | 3,174 | Reference | 1,293 | Reference
40–44 | 4,664 | 1.20 (1.13,1.28) | 6,475 | 1.16 (1.10,1.22) | 3,125 | 1.34 (1.24,1.44)
45–49 | 4,949 | 1.29 (1.21,1.37) | 7,685 | 1.32 (1.26,1.40) | 4,146 | 1.69 (1.57,1.81)
50–54 | 2,623 | 1.38 (1.28,1.48) | 4,105 | 1.35 (1.27,1.44) | 2,354 | 1.81 (1.66,1.97)
P for trend | | <.0001 | | !.0001 | | !.0001
Race/ethnicity
White | 13,512 | Reference | 20,011 | Reference | 10,186 | Reference
Black | 159 | 0.58 (0.48,0.69) | 254 | 0.56 (0.48,0.65) | 128 | 0.49 (0.40,0.60)
Hispanic | 207 | 1.09 (0.92,1.28) | 286 | 1.01 (0.87,1.17) | 159 | 1.10 (0.91,1.33)
Asian | 184 | 0.78 (0.67,0.92) | 224 | 0.71 (0.61,0.83) | 87 | 0.57 (0.46,0.72)
BMI (kg/m2)
<22 | 2,881 | 0.80 (0.76,0.85) | 3,623 | 0.78 (0.74,0.82) | 1,476 | 0.70 (0.66,0.76)
22–24 | 3,574 | Reference | 4,703 | Reference | 2,150 | Reference
25–29 | 3,905 | 1.26 (1.20,1.33) | 5,651 | 1.37 (1.31,1.44) | 2,931 | 1.52 (1.43,1.62)
>30 | 3,547 | 1.80 (1.70,1.91) | 6,544 | 2.43 (2.31,2.55) | 3,888 | 3.10 (2.91,3.30)
P for trend | | <.0001 | | <.0001 | | <.0001
Type 2 diabetes mellitus | 987 | 1.08 (1.00,1.17) | 1,678 | 1.18 (1.10,1.26) | 990 | 1.30 (1.20,1.41)
Hysterectomy | 2,295 | 1.23 (1.13,1.33) | 4,147 | 1.43 (1.33,1.54) | 2,373 | 1.59 (1.45,1.73)
Parity
None | 2,142 | Reference | 3,538 | Reference | 1,587 | Reference
1 birth | 2,038 | 1.43 (1.33,1.53) | 3,005 | 1.26 (1.19,1.34) | 1,560 | 1.48 (1.36,1.60)
2 births | 6,038 | 1.58 (1.49,1.67) | 8,783 | 1.41 (1.35,1.48) | 4,566 | 1.67 (1.57,1.79)
>3 births | 4,288 | 1.59 (1.50,1.69) | 6,113 | 1.41 (1.34,1.49) | 3,205 | 1.69 (1.58,1.82)
Oral contraceptive use
Never | 1,735 | Reference | 2,465 | Reference | 1,252 | Reference
Former | 10,954 | 1.18 (1.12,1.26) | 16,302 | 1.21 (1.15,1.28) | 8,556 | 1.20 (1.12,1.29)
Current | 1,780 | 1.04 (0.96,1.12) | 2,591 | 1.13 (1.05,1.21) | 1,071 | 0.97 (0.89,1.07)
Cigarette smoking
Never | 9,629 | Reference | 13,399 | Reference | 6,707 | Reference
Former | 3,743 | 1.00 (0.96,1.05) | 5,915 | 1.12 (1.08,1.16) | 3,012 | 1.11 (1.05,1.17)
Current | 1,115 | 0.91 (0.85,0.98) | 2,097 | 1.20 (1.13,1.28) | 1,188 | 1.34 (1.25,1.45)

Table F1-c Prevalence of UI in adults in the community

Author, Design, Adjustment for Confounding Factors, Level of Evidence | Subject Selection, Response Rate, Data Source, Methods to Measure Incontinence (survey, screening, case finding, definition of incontinence) | Subject Age, Gender, Race, Ethnicity, Residency | | | | Prevalence (%) of Urinary Incontinence, Overall; by Type, Severity, and Impact on Life
Huang, 2006 ^69^ | 603 of 2,109 women aged 40–69 years previously sampled as part of the RRISK study who enrollees in Kaiser Permanete Medical Care Program with weekly UI | Mean age: 57 (SD 9) years 50% nonwhite | | | | 50% had clinically severe UI according to the Sandvik Severity Scale
Population-based, cross-sectional survey | UI measured using self-report questionnaires: | | | | | Predictors of high impact UI (≥ 75^th^ percentile on Incontinence Impact Questionnaire) with weekly UI:
Adjusted by age, race, ethnicity, income, occupation, education, health status, fecal incontinence, number of medications, UI severity, UI type, timing of incontinence, age of onset of UI, sexual activity | During the past 12 months, on average, how often have you leaked urine, even a small amount? Additional questions asked: number of incontinent episodes that occurred in past 7 days “with an activity like coughing, lifting, sneezing, or exercise” (stress UI) or with “a physical sense of urgency” (urge UI) | | | | | High school/some college vs. college: 1.9, 1.1–3.1)
II-2b | UI severity was determined using Sandvick Severity Scale (frequency and amount of urine lost per episode) | | | | | Good health status: 3.2, 1.9–5.4
| | | | | | Fair health status: 4.6, 2.5–8.4
| | | | | | Poor health status: 14.2, 4.8–41.2
| | | | | | Fecal incontinence ≥ 1/mo: 2.2, 1.2–4.2
| | | | | | Daytime and nighttime UI vs. daytime only: 2.5, 1.3–4.9
| | | | | | Some leakage during sex: 1.9, 1.1–3.3
| | | | | | Not sexually active: 1.9, 1.1–3.3
Huang, 2006 ^70^ | 1,349 women ages 40–69 years from 2,109 women previously sampled as part of the RRISK study who were enrollees in Kaiser Permanente Medical Care Program | 345 Asian-American women ( mean age 53) | | | | Asian: 10.6% weekly, 7.8% daily
Population-based, cross-sectional mailed survey | UI measured using self-report questionnaires: | 1003 White women (mean age 58) | | | | White: 17.8% weekly, 13.0% daily
II-2a | During the past 12 months, on average, how often have you leaked urine, even a small amount? Additional questions asked: number of incontinent episodes that occurred in past 7 days “with an activity like coughing, lifting, sneezing, or exercise” (stress UI) or with “a physical sense of urgency” (urge UI) | Residence: Northern California, USA | | | | Type:
| | | | | | Asian: 7.8% stress UI, 7.3% urge UI
| | | | | | White: 15.5% stress UI, 9.5% urge UI
Fitzgerald 2006 ^71^ | Random selection from age and race strata of 2,109 women aged 40–69 years who were part of the RRISK study as enrollees in Kaiser Permanente Medical Care; 65% response rate | 598 (28%) aged 40–49 | | | | 29% weekly UI
Population-based, cross-sectional survey | UI measured using self-report questionnaires: | 796 (38%) aged 50–59 | | | | 13% weekly SUI
Adjusted by age, race, parity, BMI, and other potential confounding variables | During the past 12 months, on average, how often have you leaked urine, even a small amount? Additional questions asked: number of incontinent episodes that occurred in past 7 days “with an activity like coughing, lifting, sneezing, or exercise” (stress UI) or with “a physical sense of urgency” (urge UI) | 713 (34%) aged 60+ | | | | 206 (10%) weekly UUI
II-2A | | 1003 (48%) white | | | | 113 (5%) weekly MUI/other
| | 383 (18%) Black | | | | Childhood daytime urinary frequency:
| | 350 (17%) Hispanic | | | | SUI: 0.97 [.59–1.41]
| | 345 (16%) Asian | | | | UUI: 0.76 [0.41–1.41]
| | 29 (1%) Other | | | | Nocturia:
| | Northern California, USA | | | | SUI: 1.26 [.66–2.41]
| | | | | | UUI: 0.69 [0.19–1.44]
| | | | | | Daytime UI:
| | | | | | SUI: 1.60 [.72–5.59]
| | | | | | UUI: 2.56 [1.11–5.9]
| | | | | | Nocturnal enuresis:
| | | | | | SUI: 0.57 [.25–1.34]
| | | | | | UUI: 2.68 [1.32–5.46]
| | | | | | UTIs (1 more than year):
| | | | | | SUI: 2.00 [1.00–3.90]
| | | | | | UUI: 2.03[0.93–4.46]
Hatem, 2005 ^72^ | Random selection of 2,492 primiparous women who had given birth within a 6 month period in Quebec; 1,305 women responded (55%) with 1,291 usable responses (52% of women sent a questionnaire) | Mean age 27.2 (SD 4.8) years | | | | 29.6% UI (could include presence of fecal incontinence)
Population-based, cross-sectional survey | Mailed questionnaire at 6-months postpartum | Race/ethnicity: not reported | | | | 19.2% UI alone
No adjustments | UI measured: FPSUND tool which assessed six symptoms and their severity: frequency, use of protection, stress-related complaints, and urgerelated complaints, number of daily micturitions. Considered to have UI if had a score of 2 or more | Residence: Quebec, Canada | | | | 43% stress UI
| | | | | | 38% unspecified UI
| | | | | | 6% urge UI
| | | | | | 8% mixed UI with UUI predominant
| | | | | | 5% mixed UI with stress UI predominant
Lewis, 2005 ^73^ | 10,678 women aged 50–90 years who were participants in the Health and Retirement Study | Women aged 50–90 years | | | | 21.7% UI
Population-based, cross-sectional survey | Telephone or face-to-face interviews | 73.8% Non-Hispanic white | | | | 57% mild UI
Adjusted by race, parity, BMI, Diabetes (non-insulin dependent and insulin-dependent), hypertension, heart disease, stroke, lung disease, cancer, arthritis, ADLs | UI measured: During the last 12 months, have you lost any amount of urine beyond your control? | 14.9% African-American | | | | 43% severe UI
| Incontinence defined as mild if urine loss was reported on 15 days or fewer, and sever if reported greater than 15 days a month | 7.7% Hispanic
| | 3.6% Other
| | Residence: USA
Rait, 2005 ^74^ | 15,051 out of 20,934 eligible subjects (71.9%) obtained from patients aged 75 years and over from 106 general practices recruited to participate in the MRC Trial of the Assessment and Management of Older People in the Community Study | 61.5% female | | | | Associated with cognitive impairment (MMSE < 24):
Cross-sectional survey | Data obtained by interview; definition and measurement of UI not reported | 38.5% male | | | | UI: 1.3 [1.0–1.1]
Adjustments by age, gender, residence, marital status, health, needs, hearing, vision, medications, and falls | | 47% 75–79 years
| | 31.4% 80–84 years
| | 16.0% 85–89 years
| | 5.6% 90+ years
| | Ethnicity: not reported
| | Residence: England, Scotland, and Wales
Téllez-Zeneno, 2005 ^75^ | 49,026 participants from the National Population Health Survey (NHPS) and 130,0882 from the Community Health Survey (CHS) ages 12 years and over which represented 98% of the Canadian population (85% response rate in both surveys) | 50% female | | | | Weighted point prevalence of UI:
Population-based, cross-sectional survey | Data obtained by interview; definition and measurement of UI not reported | 50% male | | | | NHPS: 4.7 [3.4–6.2]
Adjusted by comorbidities | | Race/ethnicity: not reported | | | | CHS: 3.9 [2.7–5.3]
| | Residence: All Canadian provinces | | | | Normal vs. epileptic population:
| | | | | | Women: 14 vs. 48, prevalence ratio: 3.4 [2.5–4.5]
| | | | | | Men: 29 vs. 94, prevalence ratio: 3.2 [2.6–3.9]
| | | | | | UI: AOR 2.2 [1.7–2.9]
Ertunc, 2004 ^76^ | 154 women who underwent SUI surgery (cases) and 100 women without SUI recruited from clinics | Mean age of mothers of incontinent women: 68 (SD 9.8) and 69 (SD 8.4) of continent women | | | | SUI prevalence in mothers:
Case-control design | 70/108 mothers and 252/305 sisters (cases) | Mean age of sisters: 50 (SD 11) of incontinent women and 47 (SD 8.5) of continent women | | | | 71.4% cases
| 72/100 mothers and 207/272 sisters (control) | Turkey | | | | 40.3% controls
| Self-administered questionnaire using BLUTS: | | | | | SUI prevalence in sisters:
| SUI measurement: leakage with coughing, sneezing, or exertion after sports activities, walking, standing up from sitting position, or even sitting up in bed, leaking while erect or at least movement while lying down | | | | | 24.6% cases
| | | | | | 11.6% controls
| | | | | | Age when symptoms began lower in “incontinent families” 35 (SD 8) years vs. 41 (SD 7) years, P, .001
Hannestad 2004 ^77^ | Secondary analysis of data from the EPINCONT study: | Median age of mothers: 60 and daughters 33 | | | | Daughters increased risk:
Population-based, cross-sectional Adjusted for age, BMI, number of children, and women at risk | 6,021 mothers/8,771 recruited/13,501 available), 69% response rate 2104 older sisters from 2,426 sisters/2866 arecruited/4,456 available), 73% response rate | Median age of older sisters: 33 and younger sisters 34 | | | | UI: 13 [1.2–1.0, absolute risk: 23.3
| Self-administered questionnaire | Norway | | | | SUI: 1.5 [1.3–1.8], absolute risk: 14.6%
| UI measurement: not provided | | | | | UUI: 1.8–3.9], absolute risk: 2.6%
| | | | | | MUI: 1.6 [1.2–20], absolute risk: 8.3%
| | | | | | Younger sisters of siblings with UI, SUI, or MUI:
| | | | | | UI: 16 [1.3–1.09, absolute risk: 29.6
| | | | | | SUI: 1.8 [1.3–2.3], absolute risk: 18.3%
| | | | | | UUI: N too small to calculate
| | | | | | MUI: 1.7 [1.1–2.8], absolute risk: 10.8%
McGrother, 2004 ^26^ | Random sample of 92,491 from 154,377 people registered with 108 general practices in mixed urban and rural settings (cross-sectional survey), and 23,182 from 36,799 people for 1-year follow-up (longitudinal survey); response rate: 60.2% for prevalent sample and 63% for incident sample | Adults aged 40 and over residing in Leicestershire Health Authority, UK | | | | Female to male ratio: 2.6
Cross sectional and longitudinal mailed survey | UI measured as: do you ever leak urine when you don't mean to (day or night)? | Cross-sectional sample: | | | | UI 1-year period prevalence:
No adjustments | Stress UI: Does any urine leak when you laugh, cough, or exercise? | 50,002 women | | | | Women: Overall: 3.5% profound, 11.8% severe, 7.3% moderate, 11.6% minimal
II-A | Urge UI: Do you have such a strong desire to pass urine that you leak before reaching the toilet? | 42,939 men | | | | Men: Overall: 2.2% profound, 8.2% severe, 5.7% moderate, 8.8% minimal
| UI frequency on 5-point scale: continuously, several times a day, week, month, or never; UI volume on 4 point scale: any leakage, damp, wet, soaked. | 15% aged 65 and over | | | | UI incidence at 1-year:
| UI severity index calculated by multiplying frequency and volume scores, and categorized as minimal, moderate, severe, and profound | 85.5% white | | | | Women: 8.4% ages 40–49, 7.9% ages 50–59, 8.5% ages 60–69 years, 9.4% 70–79 years, 14.7% ages 80 and over; 8.8% overall
| | Longitudinal sample: | | | | Men: 2.2% ages 40–49, 2.5% ages 50–59, 4.0% ages 60–69 years, 7.1% ages 70–79 years, 10.9% ages 80 and over; 6.3% overall
| | 9,598 women | | | | Remission rates:
| | 7,923 men | | | | Women: 26.9% ages 40–49, 25.5% ages 50–59, 23.3% ages 60–69 years, 26.1% ages 70–79 years, 22% ages 80 and over; 25.2% overall
| | | | | | Men: 46.0 ages 40–49, 29.9% ages 50–59, 46.5% ages 60–69, 33.3% ages 80 and over, 28.8% overall
Østbye, 2004 ^28^ | 8,949 adults aged 65 and over who were participants in the Canadian Study of Health and Aging | Age at baseline: | | | | UI prevalence:
Population-based with 5 and 10-year follow-up | UI measured: Do you ever lose control of your bladder? (By that I mean, do you ever pass water when you don't intend to?) | Women: | | | | 19% women
| | 2,159 (40.6%) aged 65–74 | | | | 14.2% ages 65–68 years
| | 2,254 (42.4%) aged 75–84 | | | | 15.9% ages 70–74 years
| | 909 (11%), ages 85+ | | | | 19.7% ages 75–79 years
| | Men: | | | | 25.0% ages 80–84 years
| | 1,722 (58.9%) aged 65–74 | | | | 24.6% ages 85–89 years
| | 1,455 (40.2%) aged 75–84 | | | | 29% ages 90+ years
| | 397 (11%) age 85+ | | | | 9% men
| | Race/ethnicity: not reported | | | | 6.3% ages 65–69 years
| | Residence: Canada | | | | 7.2% ages 70–74 years
| | | | | | 9% ages 75–79 years
| | | | | | 11.2% ages 80–84 years
| | | | | | 16.6% ages 85–89 years
| | | | | | 16.9% ages 90+ years
| | | | | | Remission at 5-years:
| | | | | | 29% women
| | | | | | 38% men
Rohr 2004 ^78^ | 1168 twin pairs (548 monozygotic pairs and 620 dizygotic pairs) selected from Danish Twin Registry with data collected from 4 surveys associated with the Longitudinal Survey of Aging Danish Twins (70–94 years) and Longitudinal Study of Middle-Aged Studies (46–68 years) | 46–68 years and 70–94 years, Denmark | | | | UI prevalence: 27%
Population-based, cross-sectional | Home interview | | | | | Monozygotic twins:
| UI measured: During past month, have you involuntary been wetting yourself in connection with physical exertion, e.g., cough, life, sneeze, and laughing? (Stress UI) | | | | | 46–68 years: 17% SUI, 32% urge UI, 15% MUI
| During the past month, have you experienced such a strong urge to pass water that it was impossible to get to the toilet in time? (Urge UI) | | | | | 70–94 years: 41%% SUI, 45% urge UI, 34% MUI
| If reported > 1 leakage during past month, classified according to UI type | | | | | Dizygotic twins:
| | | | | | 46–68 years: 17% SUI, 32% urge UI, 15% MUI
| | | | | | 70–94 years: 41%% SUI, 45% urge UI, 34% MUI
| | | | | | Tetrachoric correlations:
| | | | | | Monozygotic twins:
| | | | | | 46–68 years: SUI: .05 [-0.19–.29] urge UI: 0.51 [0.26–.71]; MUI: .28 [-0.09–.59]
| | | | | | 70–94 years: SUI: .40 [.17–.60]; urge UI: .50 [.27–.68]; mixed UI: .53[.23–.75]
| | | | | | Dizygotic twins:
| | | | | | 46–68 years: SUI: .41 [.19–.60] urge UI: -0.22 [-0.59–.18]; MUI: 17 [-0.33–.60]
| | | | | | 70–94 years: SUI: .18 [-0.01–.37]; urge UI: .28 [.02–.42]; mixed UI: .33[.06–.55
| | | | | | Heritability:
| | | | | | For UUI and MUI, model including additive genetic factors and non-shared environment was best fitting model in both age groups:
| | | | | | UUI:
| | | | | | 46–68 years: 42% (17–64%)
| | | | | | 70–94 years: 49% (29–65%)
| | | | | | SUI: best-fitting model was based solely on familial and individual-specific environment: 39% (19–57%)
Nygaard, 2003( ^79^ ) | 5,701 women aged 50–69 years who participated in the third interview of the Health and Retirement Study | Age: | | | | 15.9% UI
Population-based, cross-sectional survey | Telephone interview | Continent women: 59 (SD 4) years | | | | 4.4% severe UI
Adjusted by age, depression, race, BMI, parity, education, smoking, psychiatric medication use, comorbidity index, ADL, functional status | UI measured: In the last 12 months, have you lost any amount of urine beyond your control? Mild-moderate UI was incontinence on 15 or fewer days in the last month; severe incontinence was 15 days or more of UI in last month | Mild UI: 58.5 (SD 4.1) years | | | | 10.5% mild-moderate UI
| | Severe UI: 59.6 (SD 4.2) years | | | | Risk of severe UI:
| | Race: | | | | By Composite International Diagnostic Interview (CIDI):
| | Continent: 70.4% white, 18.5% Black, 9.2% Hispanic, 1.9% other | | | | Depression: 1.82, 1.26–2.63
| | Mild UI: 81.7% White, 11.2% Black, 6.2% Hispanic, 0.9% Other | | | | Black: 0.30, 0.19–0.46
| | Severe UI: 81.7% White, 11.3% Black, 5.0% Hispanic, 2.1% Other | | | | Hispanic: 0.29, 0.15–0.53
| | Residence: USA | | | | Other: 0.77, 0.29–2.03
| | | | | | BMI: 1.44, 1.26–1.64
| | | | | | Parity: 1.27, 1.01–1.61
| | | | | | Education: NS
| | | | | | Smoking: 1.48, 1.08–2.03
| | | | | | Psychiatric medication: 1.49, 1.01–2.19
| | | | | | Comorbidity index: 1.47, 1.16–1.87
| | | | | | Functional status: 1.90, 1.49, 2.41
| | | | | | Age and ADLs interactions
| | | | | | By Center for Epidemiological Studies-Depression Scale (CES-D)
| | | | | | Depression: 1.33, 0.91–1.94
| | | | | | Black: .030, 0.19–0.46
| | | | | | Hispanic: 0.28, 0.15–0.53
| | | | | | Other: 0.82, 0.32–2.11
| | | | | | BMI: 1.44, 1.26–1.64
| | | | | | Parity: NS
| | | | | | Education: NS
| | | | | | Smoking: 1.51, 1.10–2.06
| | | | | | Psychiatric medication: 1.59, 1.08–2.34
| | | | | | Comorbidity index: 1.50, 1.18–1.90
| | | | | | Functional status: 1.92, 1.51–2.45
| | | | | | Age and ADLs interactions
| | | | | | Risk of mild UI:
| | | | | | By Composite International Diagnostic Interview (CIDI):
| | | | | | Depression: 1.41, 1.06–1.87
| | | | | | Black: 0.42, 0.31–0.56
| | | | | | Hispanic: 0.50, 0.34–0.74
| | | | | | Other: 0.36, 0.14–0.90
| | | | | | BMI: 0.97, 0.95–0.99
| | | | | | Parity: NS
| | | | | | Education: 1.30, 1.04–1.63
| | | | | | Smoking: NS
| | | | | | Psychiatric medication: 1.55, 1.16–2.07
| | | | | | Comorbidity index: 1.20, 1.02–1.41
| | | | | | ADL: 1.44, 1.10–1.88
| | | | | | Functional status: 1.55, 1.35–1.78
| | | | | | By Center for Epidemiological Studies-Depression Scale (CES-D)
| | | | | | Depression: 1.12, 0.83–1.51
| | | | | | Black: 0.42, 0.31–0.56
| | | | | | Hispanic: 0.50, 0.34–0.74
| | | | | | Other: 0.37, 0.15–0.92
| | | | | | BMI: 0.97, 0.95–0.99
| | | | | | Parity: NS
| | | | | | Education: 1.31, 1.04–1.64
| | | | | | Smoking: NS
| | | | | | Psychiatric medication: 1..64, 1.23–2.18
| | | | | | Comorbidity index: 1.50, 1.18–1.90
| | | | | | ADL: 1.46, 1.11–1.90
| | | | | | Functional status: 1.56, 1.36–1.79
Aaron, 2002 ^80^ | 200 married premenopausal and postmenopausal women aged 40–49 years in seven villages identified through the Christian Medical College and Hospital, Vellore (CHAD) census records | Mean age: postmenopausal women: 46.6 (SD 2.2) and premenopausal: 45.4 (SD 2.3) | | | | Stress UI:
Case-control study | Interview | | | | | 20% premenopausal women
| UI definition: not reported | | | | | 22% postmenopausal
Fitzgerald, 2002 ^81^ | Convenience sample of 269 from 500 women (54% response rate) employed by a manufacturing and distribution center | Women with mean age of 40 (SD 9.9) years, range 16–69 years, 85.3% age 50 years or younger | | | | Monthly UI prevalence: 29%
Cross-sectional survey design | UI measured: Have you ever lost urine when you were not able to get to the toilet in time? Have you ever lost urine when you are asleep? Have you ever lost urine when you laugh, cough, or sneezed? | 87.3% White | | | | Of those with UI:
II-2b | | 4.1% Black | | | | 88% White
| | 8.6% Asian/Native American/Other | | | | 11% Asian/Native American/Other
| | Northeastern, USA | | | | < 1% Black
| | | | | | 26% stress UI
| | | | | | 1% urge UI
| | | | | | 73% mixed UI
Langa, 2002 ^82^ | 7,443 adults aged 70 years and over who were participants in the Asset and Health Dynamics among the Oldest Old (AHEAD) cohort of the Health and Retirement Study | Mean age of continent adults: 77.2 (SD 0.2), and incontinent without pad use: 78.1 (SD 0.5), and incontinent with pad use: 79.3 (SD 0.6) | | | | 13% men
Population-based, cross-sectional survey | Interviews | 30.3% men | | | | 24% women
| UI measured: During the last 12 months, have you lost any amount of urine beyond your control. Use of absorbent products indicating UI severity | 69.7% women | | | | 9.9% UI with pad use
| | 89% White | | | | 9.5% UI -no pad use
| | 9.3% Black
| | 1.7% Other
Nuotio 2002 ^83^ | 1,052 persons (524 men and 528 women) randomly selected from the Tampere Longitudinal Study on Aging | Adults aged 60–89 years, Finland | | | | Men at 10-years (N=524):
Population-based, prospective cohort | In 10-years: 175 men and 260 women were re-interviewed in their home or in institutions | | | | | UUI at baseline: 5% (n=28)
Adjusted for chronic diseases and ADL disability | UI Measured: Do you ever have trouble getting to the lavatory in time? If, yes do you have urinary leakage, either day or night—never, rarely, frequently? | | | | | 89% (n=25) deceased
| Urge UI: urgency and urinary leakage regardless of the frequency of urine loss | | | | | 7% (n=2) no urgency
| | | | | | 4% (n=1) UUI
| | | | | | Urgency, no incontinence at baseline: 7% (n=30)
| | | | | | 83% deceased
| | | | | | 8% no urgency
| | | | | | 6% urgency, no incontinence
| | | | | | 3% urge UI
| | | | | | No urgency at baseline: 88%
| | | | | | 57% deceased
| | | | | | 3% urgency, no incontinence
| | | | | | 3% UUI
| | | | | | 7% not known
| | | | | | Women at 10-years (N=528):
| | | | | | UUI at baseline: 6%
| | | | | | 68% deceased
| | | | | | 6% no urgency
| | | | | | 26% UUI
| | | | | | Urgency, no incontinence at baseline: 7%
| | | | | | 83% deceased
| | | | | | 8% no urgency
| | | | | | 6% urgency, no incontinence
| | | | | | 3% urge UI
| | | | | | No urgency at baseline: 88%
| | | | | | 57% deceased
| | | | | | 3% urgency, no incontinence
| | | | | | 3% UUI
| | | | | | 7% not known
MacLennan 2000( ^84^ ) | Random selection of 4,400 households; 3,010 men and women (73.3% response rate) aged 15–97 years who were part of the South Australian Health Omnibus Survey | 48.7% (n=1,464) men, mean age: 42.9 years | | | | Men:
Population-based, cross-sectional survey | In-home interviews | 51.3%(n=1,546) women | | | | 1.5% stress UI
| UI measured: stress UI (loss of urine with coughing, laughing, or sneezing) or urge UI (suddenly felt urge to go to the toilet but accidentally wetting themselves before reaching toilet) | Race and ethnicity not reported; 75.3% born in Australia/Oceania, and 24.7% born overseas | | | | 1.9% urge UI
| | Residence: South Australia | | | | 1.0% mixed UI
| | | | | | 4.4% UI
| | | | | | Highest in those aged 75+ (17.6%)
| | | | | | Women:
| | | | | | 20.8% stress UI
| | | | | | 2.9% urge UI
| | | | | | 11.6% mixed UI
| | | | | | 35.3% UI
| | | | | | Highest in aged 70–74 (51.9%)
| | | | | | UI type (OR for female vs. male)
| | | | | | Stress UI: 17.2 [10.9–27.5]
| | | | | | Mixed UI: 12.6 [7.3–22.4]
| | | | | | Urge UI: 1.5 [0.9–2.6]
| | | | | | Overall UI: 11.7 [8.9–15.4]
| | | | | | Associated factors in women:
| | | | | | Age:
| | | | | | 35–54 years: 2.1 [1.5–3.0]
| | | | | | 55+ years: 3.1 [2.1–4.5]
| | | | | | Method of delivery:
| | | | | | C-section only: 2.5 [1.5–4.2]
| | | | | | Vaginal only: 3.4 [2.4–4.9]
| | | | | | At least on forceps: 4.3 [2.8–6.6]
| | | | | | Both vaginal and C-section: 4.7 [2.3–9.3]
| | | | | | BMI:
| | | | | | Normal weight: 1.4 [0.9–2.2]
| | | | | | Overweight: 2.0 [1.3–3.2]
| | | | | | Obese: 2.6 [1.6–4.3]
| | | | | | Coughing most/every day: 1.6 [1.1–2.3]
| | | | | | Osteoporosis 1.8 [1.0–3.2]
| | | | | | Arthritis: 1.8 [1.3–2.5]
Hägglund 1999 ^85^ | All women (N=3,493) aged 18–70 years in the population register of Surahammar, Sweden; 3,076 responded (88% response rates) | 653 aged 18–30 years | | | | 26% overall prevalence
Population-based, cross-sectional survey | Mailed questionnaire | 626 aged 31–40 years | | | | 12% ages 18–30 years
| UI measured: For the present dime do you have a problem with involuntary loss of urine (for example when you laugh, jump, cough, or sneeze)? | 736 aged 41–50 years | | | | 20% ages 31–40 years
| | 578 aged 51–60 years | | | | 32% ages 41–50 years
| | 478 aged 61–70 years | | | | 36% ages 51–60 years
| | Race/ethnicity: not reported | | | | 28% ages 61–70 years
| | Residence: Sweden
Palmer 1999 ^86^ | Random sample of 2,000 of 4,000 women aged 18 years and over employed full-time at large urban academic center; 1,134 returned questionnaires (57% response rate), with 1,113 usable questionnaires | Mean age: 40.3 (SD 10.6) years | | | | 21% monthly UI
Cross-sectional survey | Mailed questionnaire | 72% Caucasian | | | | Incontinent vs. continent women:
| UI measurement: Have you ever lost urine when you were not able to get to the toilet in time? Have you ever lost urine when you are asleep? Have you ever lost urine when you laugh, cough or sneeze? Have you ever lost urine without meaning to at any time not mentioned above. UI defined as monthly leakage | 21% African-American | | | | ≤ 50 years: 69.3% vs. 85.1%
| | 7% Asian, Hispanic, or American Indian | | | | > 50 years: 30.7% vs. 14.9%
| | Residence: Baltimore, MD, USA | | | | African-American: 13% vs. 17.2%
| | | | | | White: 83% vs. 74.2%
| | | | | | Asian/American Indian/Other: 3.9% vs. 8.6%
Roe, 1999 ^87^ | 6,037 of 11,523 adults with usable questionnaires (52.4% response rate) aged 18 years and over randomly sampled from family physician patient registers in two health authorities in England | 2,681 men with mean age of 53.5 | | | | 9% regular UI
Population-based, cross-sectional survey | Mailed questionnaire | 3,356 women with mean age of 49.5 years | | | | Incontinent vs continent:
Adjusted by age, sex | UI measured by asking respondents “if they had ever had bladder problems,” e.g., accidentally leaking urine, having wet pants, needing to go to the toilet frequently, and not making it on time, and using aids or appliances to manage urinary incontinence. | Race: | | | | Females vs males: 11.3% vs 5.3%, P < .0001
| UI defined as 1 or more of these symptoms at least twice a month | 5,581 (90.9%) White | | | | Age: 55.7 vs. 46.2, P <.0001)
| | 33 (0.6%) Black Caribbean | | | | No associations between UI and consumption of tea, soft drinks or alcohol; associations not shown
| | 3 (<.01%) Black African | | | | Higher BMI: 26.2 vs. 24.6, P < .0001
| | 167 (2.8%) Indian | | | | No significant association for obesity and UI for men; for women: 27% vs. 13%, P < .0001)
| | 29 (0.5%) Pakistani | | | | No association found between light cigarette consumption (5 per day), moderate (5–14/day) or heavy (15 or more per day) and continence status
| | 3 (< .01%) Bangladeshi | | | | Mobility problems: 36% vs. 16%, P < .0001
| | 11 (1.8%) Chinese | | | | Foot problems: 12% vs. 2%
| | 22 (3.6%) Other Asian | | | | Less activity than people of own age: 31% vs. 12%, P < .0001
| | 38 (6.2%) Other | | | | Sleep problems: 21% vs. 9%, P < .0001)
| | Residence: England | | | | Parity: Not significant when age controlled for
| | | | | | Fetal weight > 9 pounds: 22% vs. 14%, P < .01
Mushkat 1996 ^88^ | 780 first degree female relatives of 259 women with stress UI from gynecological outpatient clinic with 474 first degree relatives of 165 matched controls | Mean age: cases 53 (SD 10.1), controls 50 (10.7) years | | | | UI prevalence: 20.3% in first degree relatives in study group, and 7.8% in control group (p < .05)
Case-control design | Clinic interview of cases and controls about female relatives | Ethnicity: not reported | | | | Mothers (P < .005)
III | UI measured: SUI symptoms (sneezing, coughing, laughing, walking, bending, or exercising) at least twice a week | Residence: Israel | | | | 34.9% cases
| | | | | | 12.7% controls
| | | | | | Sisters: (P < .005)
| | | | | | 19.9% cases
| | | | | | 6.8% controls
| | | | | | Daughters: (P = NS)
| | | | | | 6.7% cases
| | | | | | 2.9% controls
Diokno, 2007 ^89^ | Subjects from a randomly selected pool of 250,000 households that volunteered to participate in National Family Opinion surveys, balanced to match census 2000 distributions on multiple factors. | Age: 18 and above | | | | Prevalence: 12.7%
Cross-sectional | Response rate: 66.5% (n=29,903) | Mean: 50.03 (SD: 15.23) | | | | By type (of incontinent subjects): Urge: 44.6%, Stress: 24.5%, Mixed: 18.8, Other: 12.1%
Adjusted by: | Data source: Self-reported, mailed questionnaire. UI as, “Involuntary leakage or loss of urine during the last 30 days.” | Gender: Male | | | | Age | %
Age | | Race: Not reported | | | | 18–34 | 7.25
Household size | | Ethnicity: Not reported | | | | 35–44 | 7.17
Income | | Residency: United States | | | | 45–54 | 10.98
Region size | | | | | | 55–64 | 15.58
Level of evidence: III | | | | | | 65–74 | 23.82
| | | | | | 75 + | 30.19
| | | | | | Age group | Stress UI | Urge UI | Mixed UI
| | | | | | 18–35 | 38.1 | 30 | 14.76
| | | | | | 35–45 | 35.74 | 35.38 | 12.64
| | | | | | 45–55 | 30.77 | 38.91 | 16.52
| | | | | | 55–65 | 19.28 | 46.75 | 20.96
| | | | | | 65–75 | 16.67 | 53.81 | 22.62
| | | | | | 76+ | 13.22 | 56.27 | 22.37
| | | | | | Total | 24.48 | 44.63 | 18.8
| | | | | | Characteristic | Level | % among incontinent
| | | | | | UI Symptoms in the past 7 days (n = 1923) | Yes | 65%
| | | | | | Duration of symptoms (n = 1628) | >1 year | 36%
| | | | | | | 1–2 year | 20%
| | | | | | | >2 year | 44%
| | | | | | Consulted physician for UI symptoms (n = 1787) | Yes | 47%
Kinchen, 2007 ^90^ | Subjects randomly selected from all Kaiser Permanente of Northern California members seeking care within a 12 week period in 2002. Response rate: 49.7% (n=3,344) | Age: 21–75 years Gender: Female | | | | Overall: 44%
Cross-sectional | Data source: Mailed self-reported survey. Non-responders followed up with a phone call with survey over the phone or by mail. | <30: 6.9% | | | | Age group | Prevalence %
Adjusted by: | UI as, “Having leaked urine in the last 7 days”. Stress and urge symptoms were also determined. | 30-<40: 13.6% | | | | <50 | 34.3
Age | | 40-<50: 20.5% | | | | 50–64 | 50.4
Race | | 50-<60: 24.6% | | | | 65+ | 51.8
Years with Kaiser | | 60-<70: 10.5% | | | | By type -
Permanente | | 70–75: 2.5% | | | | Stress | 42.5
Medication history | | Race: White: 57.3%, Black: 9.5%, Asian: 7.0%, Hispanic: 7.0%, American Indian: 0.8%, Other/unknown: 18.5% Ethnicity: Not reported | | | | Urge | 12.7
Surgical history | | | | | | Mixed | 43.4
Level of evidence: III | | | | | | By severity-
| | | | | | Reported as “bothersome”: 61.8%
Altman, 2006 ^2^ | 304/309 (98% response rate) primparous women who had a vaginal delivery over a 10-week period in 1995 | Swedish women with mean age at index delivery 29.9±4.1 years | | | | Prevalence rates:
Prospective, cohort study with 10-year followup | Excluded: Elective or acute cesarean delivery; inadequate knowledge of Swedish language; dual pregnancy | | | | | - Mild UI at index delivery: 5%,16/309, 95% CI 3–8, and at 10-year followup: 31%, 72/229, 95% CI: 25–37; - Moderate-severe UI at index delivery: 2%, 5/309, 95% CI 1–4, and at 10-years followup: 18%, 27/229, 95% CI: 11–23
Adjusted by maternal age and parity | 229/309 (74.1% from original sample) available and met eligibility criteria at 10 years | | | | | Mild SUI at the following time points:
Level II-2A | Excluded: UI surgery, C-sections after index delivery | | | | | - 5% (n=16/304) at baseline; - 14% (n=41/287) at 5 months; - 47% (n=17/278) at 9 months; - 25% (n=57/230) at 5 years; - 31% (n=71/229) at 10 years; - P <.001 5 months, 9 months, 5 yrs, 10 yrs
| UI Measurement by survey with self-administered questionnaire | | | | | Moderate-severe SUI:
| - Do you experience sudden desires to void urine that are difficult to hold back?; - Do you experience involuntary loss of urine at physical activities?; - Do you experience bladder emptying difficulties? | | | | | - 2% (n=5/304, 95% CI 1–4) at baseline; - 43% (n=15/287) at 5 months; - 7% (n=19/278) at 9 months; - 11%(n=24/230) at 5 years; - 12% (n=27/229) at 10 years; - P <.001 at 5 months, 9 months, 5 years, 10 years
| UI Severity Definition
| - Mild SUI defined as less than once/week; - Moderate-severe SUI defined as UI more than once per week or daily
Altman, 2006 ^91^ | 48/52 female patients (92%) with history of abdominal rectal prolapse surgery (65.8% of the 73 patients who had the surgery and were alive at the time of the study) | Swedish women with mean age of cases at followup: 69 (range 32–90), and mean age of rectopexy was 56.2 (range 26–75) | | | | 31% (n=15/48) cases vs. 24% (43/165) controls
Case-control study | 165/200 (82.5%) randomly selected age matched controls | Median parity: 2.0 (range 0–4) | | | | SUI: 17% (8/48) cases vs. 16% (26/165) controls
Mean duration of followup: 13.8 years (range 3–23) | UI Measurement: mailed survey with questions on UI (no definition, time frame, or specific question(s) provided) | Mean age of controls: 67.7 (range 30–91) | | | | UUI: 15% (7/48) cases vs. 10% (17/165) controls
Median followup: 14.3 years | | Mean parity: 2.1 (range 0–5) | | | | No difference in SUI prevalence between groups Adjusted OR, 95% CI = 1.0, 0.4–2.4; p =0.9
Adjusted for confounding factors | | | | | | - Control: 16% (n=26/48) Cases: 17% (n=8/165)
Level of evidence: II-3 | | | | | | No difference in UUI prevalence between groups Adjusted OR, 95% CI = 1.5, 0.6–3.8; p=0.4
| | | | | | - Control: 10% (n=17/48); - Cases: 15% (n=7)
Anger, 2006 ^92^ | Data extrapolated from 9,965 respondents in the National Health and Nutrition Examination Survey (1999–2000) to women ages 60 and over | Women ages 60 and over; age and ethnicity/race not specified; USA | | | | UI prevalence was 38% (8,929,543 of 23,477,726 US population estimates)
Cross-sectional | Multistage probability cluster design using census information | | | | | - 41% non-Hispanic white women; - 20% non-Hispanic black women; - 36% Mexican-American women
No adjustment for confounding factors | Survey | | | | | By severity:
Level of evidence: II-2C Same as 17070268? | UI Measurement: In the past 12 months, have you had difficulty controlling your bladder, including leaking small amounts of urine when you cough or sneeze (exclusive of pregnancy or recovery from childbirth)? | | | | | - 36% reported daily UI (13.7% in NHANES); - 27% (10.3%) reported weekly incontinence; - 23% had a few incontinent episodes/month; - 12% had at least yearly incontinence; - This corresponded to a prevalence rate of at least weekly UI: 24% of all women surveyed
| | | | | | Regardless of age, race/ethnicity or education, the majority of women responding yes to difficulty controlling bladder had at least weekly UI. The exception was the lowest income group (PIR 0) in which 100% of women reported a few leakages a month
| | | | | | Overall prevalence rates by age ranged from 33% to 41% with highest in 75–79 year olds (44%)
| | | | | | Prevalence of daily UI increased with age, ranging from:
| | | | | | - 12.2% age 60–64; - 20.9% age ≥85; - Other numbers unable to read from graph; - 32% of women with <high school education vs. 45% of women with high school education vs. 38% of women with some college
| | | | | | Women below poverty level (PIR 0 or <1) less likely to report UI (29% and 35%, respectively) vs. women above the poverty level (40% for those with PIR from 1.0 to 1.84 and 37% with PIR >1.84)
Anger, 2006 ^93^ | Female nursing home residents at admission | Female; age and race/gender for overall group not specified; USA | | | | Prevalence with admitting or current diagnosis of incontinence in medical records and identified by the National Nursing Home Survey as having UI was 73.8% to 85.4%
Cross-sectional | 1,125,163 in 1995 | | | | | All with admitting or current UI diagnosis from medical record: (count, %, rate per 100,000 residents, 95% CI):
No adjustments | 1,156,134 in 1997 | | | | | - 1995: 13,915 (1.2%), 1,237 (949–1,524); - 1997: 20,679 (1.8%), 1,789 (1,435–2,143); - 1999: 15,979 (1.4%), 1,366 (1,050–1,681)
Level of evidence: II-3 | 1,170,065 in 1999 | | | | | From medical record from 1995–1999, UI prevalence was: UI rate was1366 per 100,000 female residents (1.4%)
| National Nurse Home Survey compared to data from medical records; Data collected in 1995, 1997, and 1999 | | | | | Age: with admitting or current UI diagnosis from medical record (count, %, rate per 100,000, 95% CI):
| UI measurement: Admission or current diagnosis of UI in medical records; National Nursing Home Survey questions that asked NH staff about the: presence of indwelling Foley catheter or ostomy, need for assistance from equipment or personnel in using toilet, and difficulty in controlling urination | | | | | - ≤74 years; - 1995: 2,443 (17.6%), 1,435 (605–2,265); - 1997: 2,408 (11.7%), 1,334 (610–2,058); - 1999: 2,827 (17.5%), 1,389 (588–2,190); - 75–84 years; - 1995: 4,159 (29.9%), 1,131 (662–1,601); - 1997: 9,029 (43.7%), 2,428 (1,679–3,176); - 1999: 5,668 (35.0%), 1,540 (972–2,107); - ≥ 85 years; - 1995: 7,313 (52.6%) 1,245 (848–1,644); - 1997: 9,242 (44.7%), 1,531 (1,085–1,978); - 1999: 7,685 (47.5%), 1,254 (823–1,683)
| | | | | | Race: with admitting or current UI diagnosis by medical record (count, rate per 100,000, 95% CI): White:
| | | | | | - 1995: 13,397, 1,340 (1,022–1,558); - 1997: 17,962, 1,779 (1,402–2,155); - 1999: 15,075, 15,075 (1,148–1,869)
| | | | | | Other:
| | | | | | - 1995: 518, 421 (0.0–905); - 1997: 2,717, 1,969 (858–3,080); - 1999: 904, 554 (58–1,051); - African Americans: 11% of incontinent vs. 10% of continent; - Hispanics: 2.8% of incontinent residents vs. 3.3% of continent residents; - Counts (%) and rates(95% CI) for those with admitting or current diagnosis of UI identified by the NNHS with difficulty controlling urine per 100,000 residents (95% CI):; - 1995: 10,695/13,915 (76.9%), 76,858 (66,543–87,176); - 1997: 15,255/20,679 (73.8%), 73,772 (64,947–82,597); - 1999: 13,648/15,979 (85.4%), 85,412 (77,364–93,460)
| | | | | | Counts (%), and rates (95% CI) for those with admitting or current diagnosis of UI identified by NHHS with indwelling foley or ostomy:
| | | | | | - 1995: 1,435/13,914 (10.3%), 10,316 (2,864–17,768); - 1997: 2,423/20,679 (6.9%), 11,718 (5,311–18,125); - 1999: 1,517/15,979 (9.5%), 9,495 (2,892–16,099)
| | | | | | Counts (%), and rates for indwelling foley or ostomy of residents regardless of continence status per 100,000 (95% CI)
| | | | | | - 1995: 101,827 (9.1%), 9,050 (8,281–9,819); - 1997: 90,855 (7.9%), 7,859(7,151–8,566); - 1999: 96,151 (8.2%), 8,218 (7,484–8,951)
| | | | | | Counts (% for those answering question but those where question skipped for allowed reason or left blank) and rates per 100,000 (95% CI) of residents with UI identified by NHHS as requiring assistance for using toilet:
| | | | | | - 1995: 9,847 (70.8%), 70,766 (59,831–81,702); - 1997: 14,237 (83.6%), 68,846 (59,267–78,424); - 1999: 8,898 (73.3%), 55,684 (43,783–67,586)
| | | | | | Counts (% for those answering question but not those where question skipped for allowed reason or left blank) and rates per 100,000 (95% CI) of residents regardless of continence status identified by NHHS as requiring assistance using toilet:
| | | | | | - 1995: 659,035 (69.7%), 70,766 (59,831–81,702); - 1997: 652,615 (70.7%), 68,846 (59,267–78,424); - 1999: 670,006 (71.0%), 55,684 (43,783–67,586)
| | | | | | Also provides rates for not requiring assistance but did not include those
| | | | | | Counts (% of those answering but not those where question skipped for allowed reason or left blank) and rates per 100,000 (95% CI) of those with UI requiring assistance from equipment when using toilet:
| | | | | | - 1995: 3,214 (33.2%), 23,095 (12,895–33,295); - 1997: 4,464 (33.0)), 21,587 (13,465–29,709); - 1999: 2,821 (32.4%), 36,771 (25,354–48,188)
| | | | | | Counts (% of those answering; does not include those who skipped question for allowed reason or left questions blank) and rates per 100,000 (95% CI) of residents regardless of UI status requiring assistance from equipment when using toilet:
| | | | | | - 1995: 182,813 (28.4%), 23,095 (12,895–33,295); - 1997: 180,518 (29.4%), 21,587, (13,465–29,709); - 1999: 178,305 (27.6%), 36,771 (25,354–48,188)
| | | | | | UI prevalence with an admitting or current diagnosis of UI in medical records: 73.8%-85.4% identified in NNHS as having difficulty controlling urination
| | | | | | Regardless of record-based continence status: 56.3% to 58.6% had difficulty controlling urine
| | | | | | Counts (% of those answering; does not include those who skipped question for allowed reason or left questions blank) and rates per 100,000 (95% CI) of residents with UI requiring assistance from a person when using toilet:
| | | | | | - 1995: 9,619 (97.7%), 69,132 (58,007–80,256); - 1997: 14,000 (100%), 67,698 (58,032=77,365); - 1999: 8,675 (97.5%) 54,292 (42,379–66,205)
| | | | | | Counts (% of those answering; does not include those who skipped question for allowed reason or left questions blank) and rates per 100,000 (95% CI) of residents regardless of continence status requiring assistance from a person when using toilet:
| | | | | | - 1995: 652,088 (99.1%), 57,955 (56,636,59,274); - 1997: 640,137 (98.87%) 55,369 (54,048–56,689); - 1999: 661,92799.0%), 58,608 (57,288–59,927)
Anger, 2006 ^94^ | Data extrapolated from 9,965 respondents ≥60 years in the National Health and Nutrition Survey (1999-2000), comparing men to women. Multistage probability cluster design using census information and cross-sectional data | Men and women aged 60 years and over; ethnicity/race not specified; USA | | | | Prevalence rate of 17% (3,131,814 of 18,231,934 extrapolated from US estimates)
Cross-sectional | Survey | | | | | By race:
No adjustment for confounding factors | [underlined: UI measurement]: In the past 12 months, have you had difficulty controlling your bladder, including leaking small amounts of urine when you cough or sneeze? | | | | | - 21% Non-Hispanic black men; - 16% Non-Hispanic white men; - 14% Mexican-Americans
Level of evidence: II-2C | | | | | | By education:
| | | | | | - 20% <high school education; - 15% high school education; - 16% some college
| | | | | | By income level:
| | | | | | - 55% <poverty level (PIR of 0); - Higher income groups had less
| | | | | | By UI severity:
| | | | | | - 42% (7% of all men) reported daily UI; - 24% (4% of all men) reported weekly UI
| | | | | | By age and severity:
| | | | | | - 50% aged 75–79 had daily UI (highest among age groups reporting daily UI); - 37% aged 60–64 had weekly UI (Highest among age groups reporting weekly UI); - Among all age groups, with daily or weekly UI ranged from 62% aged 86 and over to 71% in the 60–64 age group
| | | | | | In comparison to NHANES data between men and women older than 60 years:
| | | | | | - Prevalence in men is <1/2 that in women (17% vs. 38%); - UI prevalence in men increased with age and peaked in 85 and over (31%), whereas, women prevalence peaked in 75–79 year (44%); - Prevalence of UI among black men nearly same as black women (21% vs. 20%); - Black men had highest prevalence of UI vs. Black women who had the lowest prevalence of UI; - Differences noted by socioeconomic status between genders; - Men with less than high school degree had highest prevalence whereas women with less than high school degree had lowest prevalence; - Stratification by poverty yielded similar gender disparity with prevalence highest among poor in men but lowest in poor women
Brown, 2006 ^95^ | 1,461/2,531 (57.7%) nonpregnant female participants aged ≥20 years in the NHANES study (2001–2002) with diabetes or impaired fasting glucose Excluded: incomplete UI information, did not complete physical examination, without diabetes diagnosis and had not fasted 8 hours before laboratory testing | Female, USA | | | | Prevalence of UI:
Cross-sectional | - 246 (16.8%) had diabetes (self-report of FBS ≥ 126 mg/dl); - 146 (11.2%) had impaired fasting glucose (FBS 100–125 mg/dl) | Mean age ( P <.001) | | | | - Similar between those with diabetes (35.4%) and impaired fasting glucose (33.4%); - Higher than those with normal fasting glucose (16.8%; P <.001); - Based on these numbers, researchers estimate ~ 12.7 million women have UI, with 1.9 million prediabetic women (95% CI: 1.3–2.5) and 2.5 million women with diabetes [2.1–2.9]
Adjusted for BMI | Stratified, multistage probability cluster design | - 60.2 ± 1.5 diabetic women; - 58.0 ± 1.1 prediabetic women; - 44.0 ± 0.8 normal glucose women | | | | Type of UI
Level of Evidence: II-2C | Survey | Race: (P= .24) | | | | - ≥ weekly UUI more common in diabetic (26.4%) and prediabetic (24.6%) women vs. normal women (7.7%, (P <.001); - ≥ weekly SUI more common in diabetic (30.2%) and prediabetic (31.2%) women vs. normal women (14.4%, P <.001); - Bothersome UI is greater among diabetic (31.3%) and prediabetic (24.7%) women than normal women (18.2%, P <.01); - Impact on daily activities Is greater among diabetic (12.6%) and prediabetic (14.0%) vs. normal women (4.9%, P <.001)
| UI measurement using self-administered questionnaire: During the past 12 months, have you leaked or lost control of even a small amount of urine with an activity like coughing, lifting, or exercise (stress incontinence) and “with an urge or pressure to urinate and could not get to the toilet fast enough?” (urge incontinence) | - Non-Hispanic white; - 104 (42.3%) Diabetic; - 90 (54.9%) Prediabetic; - 565 (53.8%) Normal glucose; - Non-Hispanic black; - 59 (24.0%) Diabetic; - 90 (54.9%) Prediabetic; - 188 (17.9%) Normal glucose; - Mexican-American; - 65 (26.4%) Diabetic; - 32 (19.5%) Prediabetic; - 225 (21.1%) Normal glucose
| Primary outcome: weekly or more frequent UI
| Bothersome UI and impact of UI: asked to rate degree of worry created by urine leakage and affect of urine leakage on day-to-day activities (categorized by not at all, only a little, versus somewhat, very much, or greatly
Danforth, 2006 ^68^ | 83,355 women who provided information on UI and parity out of 101,294 women who were sampled (82.3% response rate) | Women, mean age 44.8 years, USA | | | | Leaked urine in past 12 months: (%) (n's available)
Cross-sectional | Nurses Health Study II | | | | | - 57% never or <1 time/month; - 17% 1–3 times/month; - 26% 1 time/week
Adjusted for BMI, Type II Diabetes, hysterectomy, parity, oral contraceptive use, cigarette smoking | Mailed survey | | | | | By race (%)
Level of evidence: II-A | UI Measurement: During the last 12 months, how often have you leaked or lost control of your urine? (never, <1 time/month, 1x/month, 2–3 x/month, 1 time/week, almost every day) | | | | | - Never or <1 time/month; - 56% White; - 64% Black; - 55% Hispanic; - 14% Asian; - 17% other or missing; - 1–3 times per month; - 18% White; - 15% Black; - 19% Hispanic; - 14% Asian; - 17% other/missing; - 1time/week; - 26% White; - 22% Black; - 26% Hispanic; - 18% Asian; - 25% Other/missing
| If you lose urine, how much usually leaks? (a few drops, enough to wet underwear, enough to wet outer clothing, enough to wet floor) | | | | | Quantity of urine leaked:; - 41% a few drops; - 53% enough to wet underwear; - 6% enough to wet outer clothing/floor
| Created two cases:; 1) occasional urine loss (leaking 1–3 times/month; 2) frequent urine loss (leaking at least weekly) | | | | | Quantity of urine leaked by race/ethnicity:; - A few drops; - 41% White; - 35% Black; - 36% Hispanic; - 49% Asian; - 40% Other/missing; - Enough to wet underwear; - 53% White; - 62% Black; - 58% Hispanic; - 4% Asian; - 6% Other/Missing; - Enough to wet outer clothing/floor; - 6% White; - 4% Black; - 6% Hispanic; - 4% Asian; - 6% Other/missing
| Severe UI=enough to wet underwear | | | | | After adjustment for confounding factors (see table on supplemental evidence table for risk factors):
| | | | | | - Significant trend of increasing prevalence with increasing age
| | | | | | Women ages 50–54 years had 1.81 times the odds of severe UI compared to women <40 (95% CU 1.66–1.97). After adjustment, Black (OR 0.49, 95% CI: .40–.60) and Asian-American women (OR: .57, CI: .46–.72) were at reduced odds of severe incontinence compared to white women; Hispanic and White women did not differ in UI prevalence
Glazener, 2006 ^5^ | 3,405/4,537 (75.1% response rate) of women responding they had singleton births delivered over 1-year between 1994–1995 (3489/4555 responded to survey) | Women mean age 26.7 years (SD 5.3), Scotland, New Zealand, and England | | | | UI prevalence: 29%
Cross-sectional | Excluded: Twin pregnancies | Race/ethnicity not reported | | | | UI frequency at 3 months:
Adjusted | Mailed survey | | | | | - 50% (n=485) <1 time/week; - 41% (n=401) <daily and >once per week; - 9% (n=88) >daily leakage
Level of evidence: | UI Measurement: A positive response to one or more of the following questions:; - At present, do you ever lose any urine when you don't mean to?; - In the last month, how often has this happened on average?; - Do you wear a pad for this? | | | | | UI pad usage at 3 months
| | | | | | - 68% (n=664) none; - 23% (n=221) sometimes; - 10% (n=98) daily
| | | | | | Effect on quality of life at 3 months:
| | | | | | - 51% (n=462) hygiene; - 47% (n=342) home, work, social life; - 17% (N=140) sex life
| | | | | | UI Type at 3 months:
| | | | | | - 48% (n=459) SUI; - 23% (n=221) UUI; - 15% (n=285) MUI
| | | | | | Co-existing FI at 3 months:
| | | | | | - 15% (n=136)
| | | | | | After adjustments were made, the change of UI was increased with maternal age
Irwin, 2006 ^96^ | 19,165/58,139 adults aged ≥ 18 years (33% response rate) who were participants in the EPIC Study | Women and men residing in Canada, Germany, Italy, Sweden, and UK | | | | UI
Population-based, cross-sectional | Interview | 95.6% white | | | | - 13.1% women; - 5.4% men
Not adjusted | UI Measurement: How often do you experience urinary leakage? | Percent of women and men not reported | | | | UI type by age and gender: See supplemental table
Level of evidence: II-2A
MacArthur, 2006 ^67^ | 4,214/7,872 women who had a childbirth during 1993–1994 and had responded to a 3 month questionnaire (54% response rate) | Women mean age 26.7 years (SD 5.3), Scotland, New Zealand, and England | | | | Prevalence of persistent UI at both 3 months and 6 years was 24%
Prospective cohort study with 6 year followup | Conducted in 3 countries | Race/ethnicity not reported | | | | Severity of persistent UI at 6 years:
Followup from Glazener, 2006 report | Mailed survey 3 months and 6 years after index birth | | | | | - 12% (120/1010) daily UI; - 21% (208) a few times a week; - 23% (231) sometimes used a pad; - 11% (111) used a pad all day and/or all night
Adjusted for maternal age, delivery mode, and parity | UI Measurement: A positive response to one or more of the following questions:; - At present, do you ever lose any urine when you don't mean to?; - In the last month, how often has this happened on average? | | | | | UI impact of persistent UI at 6 years:
Level of evidence: II-2A | Do you wear a pad for this? | | | | | - 47% (477) hygiene; - 16% (166) home life; - 35% (356) social life; - 21% (162/783 who worked) work life; - 13% (120/915 with partner) on sex life
| | | | | | Median VAS assessing overall extent of problem = 25.0 with 22% (226) scoring 50 or more (higher scores=worse)
Lewinshtein, 2006 ^97^ | 366 men aged 33–80 years participating in a prostate cancer screening | Men with a median age of 54.8 years; Quebec, Canada | | | | Defines UI as SUI except question is worded for presence of leaked urine only
Cross-sectional | Excluded: diagnosis of prostate cancer | 226 (76.4%) Caucasian | | | | UI prevalence by age and severity n, (%):
Stratified by age and comorbidity (e.g., circulation problems and diabetes and tested using Chi-square tests | Self-administered questionnaire | 14 (4.7% African-American | | | | - <50 years; - Daily: 0; - 1 time/week: 4 (3.5%); - < 1 time/week: 3 (2.7%); - Never: 106 (93.8%); - 50.1–60 years; - Daily: 4 (3.4%); - 1 time/week: 1 (0.9%); - <1 time/week: 8 (6.8%); - Never: 104 (88.9%); - >60 years; - Daily: 5 (7.0%); - 1 time/week: 1 (1.4%); - < 1 time/week: 4 (5.6%); - Never: 61 (85.9%); - Total; - Daily: 9 (3.0%); - 1 time/week: 6 (2.0%); - <1 time/week:15 (5.0%); - Never: 271 (90.0%)
Level of evidence: | UI Measurement: Over the past 4 weeks, how often have you leaked urine? | 56 (18.9%) Other | | | | Urinary bother by age, n (%)
| Overall, how big a problem has your urinary function been for you during the last 4 weeks? | | | | | - <50 years; - Big problem: 0; - Moderate problem 1 (0.9%); - Minor problem: 8 (7.2%); - Very minor problem: 11 (9.9%); - No problem: 91 (82%); - 50.1–60 years; - Big problem: 3 (2.5%); - Moderate problem 5 (4.2%); - Minor problem: 5 (4.2%); - Very minor problem: 16 (13.6%); - No problem: 89 (75.4%); - > 60 years; - Big problem: 1 (1.4%); - Moderate problem: 3 (4.1%); - Minor problem: 3 (4.1%); - Very minor problem: 16 (21.6%); - No problem: 51 (68.9%); - Total; - Big problem: 4 (1.3%); - Moderate problem: 9 (3.0%); - Minor problem:16 (5.3%); - Very minor problem: 43 (14.2%); - No problem: 231 (76.2%)
| | | | | | Urinary bother, regardless of UI severity, significantly increased with age ( P <.001)
| | | | | | UI was not associated with age (P <.07)
Mardon, 2006 ^98^ | Baseline surveys: 145,765 (67% response rate) community-dwelling Medicare beneficiaries ≥65 years | Men and women ≥65 years, USA | | | | UI in past 6 months (P <.001)
Cross-sectional | Excluded: institutionalized individuals and <65 years | Race/ethnicity: | | | | - 43.6% women; - 27.9% men; - Overall: 37.3%
Adjusted by age, sex, race, Hispanic status | Random sample | - 8,343 Hispanics; - 133,860 Non-Hispanics; - 5,626 American Indians; - 3,047 Asians; - 10,775 African-Americans; - 125,154 Whites; - 3,863 Other | | | | By age:
Level of evidence: II-2C | Medicare Health Outcomes Survey (Mailed) | | | | | - 31.9% age 65–69; - 34.0% age 70–74; - 37.9% age 75–79; - 41.1% age 80–84; - 49.3% age 90–94; - 54.3% ≥age 95
| 86,708 women | | | | | By race/ethnicity:
| 58,470 men | | | | | - 30.6% Hispanics; - 37.9% Non-Hispanics; - 38.7% American Indians; - 31.6% Asians; - 30.3% African-Americans; - 38.3% Whites; - 31.2% other
| Mailed survey | | | | | Impact (big, small)::
| UI Measurement: UI in past 6 months | | | | | - 19.2%, 58.0% women; - 13.4%, 57.5% men; - 17.3%, 58.8% overall
| UI described as not a problem, a small or big problem | | | | | Big impact by age
| | | | | | - 13.6% age 65–69; - 14.7% age 70–74; - 18.2% age 75–79; - 19.0% age 80–84; - 22.6% age 85–89; - 27.0% age 90–94; - 37.5% ≥age 95
| | | | | | By race and impact (big
| | | | | | - 58.9% Hispanic; - 55.4% Non-Hispanic; - 58.7% American Indian; - 53.6% Asian; - 55.1% African-American; - 55,3% White; - 61.3% Other
McGrother, 2006 ^6^ | 12,570/19,241 (65.3% response rate) com40–98munity-dwelling women drawn from 108 general practices (71% of all practices) | Women aged ≥40 years (range 40–98), UK | | | | At baseline:
Prospective cohort study with 1-year followup | Mailed questionnaire at baseline and 1 year | Median age: 58 years | | | | - Pure SUI: 837/12,570 (6.7%)
Adjusted for age and ADL; separate models adjusted for general and specific morbidities and parity | UI Measurement: SUI: leakage upon laughing, coughing, or exercise ≥monthly
Level of evidence: II-2A | OAB included but could not differentiate those with OAB with urge incontinence from those with OAB without urge incontinence
Thom, 2006 ^99^ | 2,108 out of 10,230 women initially invited who were enrolled in the Kaiser Permanente Medical Care Program of Northern California since age 18 and have at least half of births with Kaiser system | Women ages 40–69 years, Mean age 56 (SD 8.6) years; USA | | | | UI prevalence in past 12 months by frequency and adjusted for age (OR, 95% CI):
Cohort study (cross-sectional) | 2,108/3,240 enrolled (65.1% response rate) | Race/ethnicity status: | | | | - Any incontinence (P =.0068); - White: 73.3, 71.4–75.2; - Hispanic: 74.8, 73.0–76.7; - Black: 64.8, 62.8–66.9; - Asian: 68.8–66.9–70.8; - Monthly or more (P <.0001); - White: 45.0, 42.9–47.1; - Hispanic: 51.0, 48.9–53.1; - Black: 36.8, 34.7–38.9; - Asian: 33.7, 31.7–35.8; - Weekly or more (P<.0001); - White: 29.6, 27.7–31.6; - Hispanic: 35.9, 33.9–38.0; - Black: 25.2, 23.2–27.0; - Asian:19.0, 17.3–20.7; - Daily (P =.0077); - White: 12.1, 10.7–13.5; - Hispanic: 17.2, 15.5–18.8; - Black: 11.8, 10.4–13.2; - Asian: 8.5, 7.3–9.7
Adjusted by age, response bias, parity, maternal age at first birth, menopausal status, hysterectomy, current oral estrogen use, BMI, Comorbidity (e.g., 1 or more UTIS in last year, Diabetes), current smoker, alcohol 1 drink/wk or more | Population-based sample with age and race stratified sampling | - 47.6% (1003) white; - 16.6% (350) Hispanic; - 18.2% (382) Black; - 16.4% (345) Asian-American; - 1.3% (28) Did not select category | | | | Incontinence severity adjusted by age (OR, 95% CI)
Level of evidence: II-2A | Self-report questionnaires and in-person interviews; medical record data abstraction | | | | | - Moderate severity (daily UI of a few drops or weekly UI which wets underwear or crotch of pants); - White: 21.2, 19.4–23.0; - Hispanic: 24.0, 22.1–25.8; - Black: 17.9, 16.2–19.5; - Asian: 13.8, 12.3–15.2; - Severe/very severe (weekly or daily UI which wets pants or floor) (P= .50); - White: 8.3, 7.1–9.5; - Hispanic: 11/7, 10.3–13.1; - Black: 7.3, 6.2–8.4; - Asian: 5.2, 4.3–6.2
| UI measurement: | | | | | UI prevalence in last week by UI type adjusted for age (any UI, SUI, UUI:
| - At least 1 self-reported UI episode in past 12 month; - SUI: Number of UI episodes over last 7 days that occurred with an activity like coughing, lifting, sneezing, or exercise; - UUI: Number of UI episodes accompanied by a physical sense of urgency; - Severity based on Sandvik Severity score | | | | | - White: 27.2%, 15,1%, 8,8%; - Hispanic: 33.1%, 17.8%, 10%; - Black: 23%, 7.5%, 13.6%; - Asian: 18.5%, 7.9%, 7.4%
| | | | | | UI prevalence at least weekly by type, adjusted for age, %, 95% CI
| | | | | | - SUI only (P <.0001); - White: 7.2%, 6.1–8.3; - Hispanic: 9.0%, 7.7–10.2; - Black: 2.3%, 1.7–3.0; - Asian: 3.4%, 2.6–4.2; - Mixed, predominantly SUI (P=.035); - White: 7.9%, 6.7–9.1; - Hispanic: 8.8%, 7.6–10.0; - Black: 5.2%, 4.3–6.2; - Asian: 4.5%, 3.6–5.4; - UUI only (P=.027); - White: 4.8%, 3.9–5.7; - Hispanic: 5.8%, 4.8–6.8; - Black: 7.6%, 6.5–8.8; - Asian: 3.0%, 2.3–3.8; - Mixed, predominantly urge (P=NS); - White: 4.0%, 3.1–4.8; - Hispanic: 4.2%, 3.3–5.0; - Black: 6.0%, 5.0–7.1; - Asian: 4.4%, 3.5–5.2; - Mixed, equal SUI and UUI (P= NS); - White: 3.3%, 2.5–4.1; - Hispanic: 5.3%, 4.3–6.3; - Black: 1.9%, 1.3–2.5; - Asian: 3.2%, 2.5–4.0
| | | | | | Readjusted rates of weekly UI considering response bias of no enrolled women:
| | | | | | - White: From 29.6% to 26.0%; - Hispanic: From 36.0 % to 25.5%; - Black: From 25.3% to 17.0%; - Asian: From 19.1% to 14.3%
| | | | | | Readjusted rates by UI type considering response bias of no enrolled women: (Any UI, at least 1 time/month, once per week, daily UI)
| | | | | | - White: 69.2%, 43.3%, 29.2%, 12.4%; - Hispanic: 61.2%, 40%, 28.5%, 13.4%; - Black: 50.5%, 29%, 19.7%, 9.9%; - Asian: 56.1%, 29.2%, 15.9%, 6.3%; - Prevalence was significantly lower in black and Asian-American women compared to white and Hispanic women (P <.001)
| | | | | | After adjustment for age, parity, hysterectomy, estrogen use, BMI, menopausal status, and diabetes:
| | | | | | - SUI risk lower in black (adjusted OR 0.36, 0.23–0.57) and Asian-American (adjusted OR .54, 0.34–0.86) compared to white women; - UUI risk similar in black (adjusted OR 1.19, 0.79–1.81) and Asian-American (adjusted OR .86, .52–1.43) compared to white women
Wehrberger, 2006 ^9^ | 441/925 women (47.7% response rate) who completed a free examination in 1998 or 1999 | Women aged 20–84 years; Austrian | | | | UI prevalence:
Prospective cohort study with mean duration of follow-up of 6.5 years | Mailed questionnaire | | | | | - 32% at baseline; - 43% at 6.5 years
Adjusted for confounding factors | UI Measurement: BFLUTS: Have you leaked any urine at all during past 4 weeks?
Level of evidence: II-2A
Jackson, 2006 ^100^ | Randomly selected 1,107 women from Group Health Cooperative enrollees from 1998 to 2002 which included 799 nondiabetic women and 218 diabetic women (26% of total number of eligible nondiabetic and diabetic women) who were participants in a longitudinal study on urinary tract infection risk | Women ages 55–75 years; USA (Washington state) | | | | Baseline prevalence of any amount of frequency of UI was 66% and 8% with severe incontinence in past year (see Jackson, 2005 ^101^
Prospective cohort | Excluded: Natural menstrual cycle in past 12 months; nursing home care, wheel chair bound, dementia, severe psychiatric disorder, indwelling or intermittent catheterization, end-stage renal disease requiring dialysis, active malignancy other than skin cancer, acute cystitis in past 90 days, chronic antibiotic use; enrollment in GHC <1 year | 87.6% White
Adjusted for diabetes | Mailed survey, clinic interview, and computerized laboratory, hospital, and pharmacy records collected at baseline, 12 and 24 months | 4.5% African-American
Level of evidence: II-2A | UI measurement: Report of any UI or severe UI at 12 or 24-month followup visits using question: | 4.9% Asian or Pacific Islander
| Have you had accidental leakage of your urine during the past year. | 3.0% Other (from Boyko, 2005 which first described the sample)
| Approximated the Sandvik index for incontinence severity
Lukacz, 2006 ^102^ | Age-stratified random selection in 4 age strata | Women ages 25–84 years in 4 age strata: 25–39, 40–54, 55–69, and 70–84 years | | | | SUI overall prevalence: 15% (511/4043)
Cross-sectional | 4,458/12,200 (37%) respondents participating in the Kaiser | USA | | | | Prevalence by birth group, %, 95% CI
Adjusted by age, obesity, parity, menopause, caffeine, diabetes, and delivery method | Permanente Continence Associated Risks Epidemiology Study | 60% non-Hispanic White | | | | - Nulliparous: SUI: 8%, 6–10; n=64/771; - C-Section: SUI: 11%, 8–15, n=43/387; - Vaginal delivery: SUI: 18%, 16–19, n=505/2,885; - P <.05 for difference between C-section vs. nulliparous and vaginal delivery vs. nulliparous; P <.05 for differences between vaginal and C-section delivery
Level of evidence: II-2 | 4,103 available for analysis | 20% Hispanic
| Mailed survey | 10% African American
| UI Measurement: See previous publications | 8% Asian-Pacific Islander
| | 1% American Indian
| | 1% Other or unknown
Tannebaum, 2006 ^103^ | Population-based sampling of women ages 55 years and over who responded to a 2002 survey on older women's priorities for healthy aging | Women ages 55 years and over; 10 Canadian provinces | | | | Overall prevalence: 39%
Cross-sectional (population-based) | 2,361/5,000 women (47% response rate; 15%-18% response rate from all Canadian households | Mean age 71±7 years | | | | SUI: 32.0%
No adjustment | Mailed survey | | | | | UUI: 22.0%
Level of evidence: II-2A | UI Measurement: ICI questions | | | | | MUI: 35.0%
| SUI: urine leakage with laughing, coughing, or exercising | | | | | Nocturnal UI: 7.0%
| UUI: urine leakage on way to the bathroom | | | | | UI at least once per day: 45.0%
| MUI: combination of SUI and MUI Nocturnal UI: urine leakage at night while asleep | | | | | Moderate or large amount of leakage per UI episode: 16.7%
van Brummen, 2006 ^7^ | Consecutive recruitment of nulliparous pregnant women with single, low-risk pregnancy between 12 and 18 weeks gestation recruited from 10 midwifery practices from January 2002 to July 2003 | Women with a mean age of 30.4 (SF 0.19); Netherlands | | | | Prevalence of OAB-wet symptoms:
Prospective cohort study | Exclusion criteria: previous urogynaecological surgery, urogynaecological malformations, diabetes mellitus, or neurological disorders; good knowledge of Dutch language; pregnancy within 1 year after index pregnancy | | | | | - 12 (3.5%) at 12 weeks; - 50 (14.6%) at 36 weeks; - 12 (3.5%) at 3 months; - 12 (3.5%) at 1-year
No adjustment for confounding factors | 344 (72.6%) returned all questionnaires
Level of evidence: II-2A | Self-report questionnaire at 12, 24, and 36 weeks gestation, and 3 and 12 months after delivery
Note: van Brummen, 2006 ^8^ had similar sample but recruited from fewer midwifery practices over same time period and van Brummen, 2006 ^7^ had similar sample size | UI Measurement (OAB-wet):
| Using questions from the UDI,
| - Wet OAB: Do you experience a strong feeling of urgency to empty your bladder? Do you experience frequent urination? Do you experience urine leakage related to the feeling of urgency? All 3 questions must be answered positively to have OAB-wet
| Measured impact by IIQ
| Baseline continence status unknown
Van Brummen, 2006 ^8^ | Consecutive sample 1,366 nulliparous pregnant women with single, low-risk pregnancy between 12 and 18 weeks gestation recruited from 8 midwifery practices from January 2002 to July 2003 | Women with a mean age 30.4 years (SD 3.9, range 20–40); Netherlands | | | | At 12 weeks gestation:
Prospective cohort study | Exclusion criteria: previous urogenital surgery, diabetes mellitus, or neurological disorders; non-Dutch speaking | Race not specified | | | | - UUI: 33 (6.4%); - SUI: 96 (18.6%)
No adjustment for confounding factors | 515/1244 eligible women (41.4%) | | | | | At 36 weeks gestation:
Level of evidence: II-2A | Self-report questionnaire at 12, 24, and 36 weeks gestation, and 3 and 12 months after delivery | | | | | - UUI: 99 (19.2%); - SUI: 217 (42.1%)
See van Brummen, 2006 ^7^ (different N and number of practices but can be similar study population) | UI Measurement: | | | | | Symptom bother (denominator—all subjects):
| Using questions from the UDI, | | | | | - UUI: 2 (0.2%) at 12 weeks; 15 (2.9%) at 36 weeks; - SUI: 12 (2.3%) at 12 weeks; 29 (5.6%) at 36 weeks
| - SUI was defined as: Do you experience urine leakage related to physical activity, coughing, or sneezing?; - UUI: Do you experience urine leakage related to the feeling of urgency? | | | | | Symptom bother at 36 weeks of those with the symptom:
| Defined symptom bother using item levels and total scores from UDI | | | | | - UUI: 15/99 (15.2%); - SUI: 29/217 (13.4%)
| Baseline continence status unknown
Viktrup, 2006 ^104^ | Consecutive sample of 241/305 primiparous women (79%) | Women with a mean age during first delivery 26 (range 17–41); Norway | | | | Prevalence of SUI:
Prospective cohort study with 12-year followup after first pregnancy | Excluded: UUI symptoms | Race not specified | | | | - Before 1st pregnancy: 3.7% any SUI, 0.4% daily SUI, 0.4% social/hygienic problem; - 30.7% any SUI during 1st pregnancy, 5% daily SUI, and .8% social or hygienic problem; - 18.7% any SUI during 1st puerperium, 5% daily SUI, 2.5% social/hygienic problem; - 5.8% any SUI 3 months after 1st delivery, 1.2% daily SUI, 0.4% social/hygienic problem; - 29.5% any SUI 5 years after 1st delivery, 6.2% daily SUI, 8.3% social/hygienic problem; - 42.3% any SUI 12 years after 1^st^ delivery, 5.4% daily SUI, and 8.7% social/hygienic problem. 12 years after first delivery, SUI prevalence:; - 42% (102/241); - 5.4% (13/241) had daily SUI; - 8.7% (21/241) complained of hygienic or social discomfort because of SUI
Not adjusted | Data obtained from birth registration records, hospital records, telephone interviews a few days after first delivery, 3 months; and mailed questionnaire at 5 and 12 years | | | | | SUI prevalence by vaginal delivery:
Level of evidence: II-2A | UI measurement (using ICS definitions): Do you have UI provoked by physical exertion? Do you have daily incontinence? Whether UI was a hygienic or social problem? | | | | | 33.0% (38/115) vaginal delivery in those without SUI before or during pregnancy
| | | | | | 60.8% (31/51) with SUI in 3 months postpartum OR 3.1, CI: 1.6–6.2)
| | | | | | SUI prevalence by C-section delivery
| | | | | | - 19.4% (6/31) without SUI before or during pregnancy; - 40.0% (6/15) with SUI 3 months postpartum; - OR 2.8, CI: 0.7–10.9)
Teleman, 2005 ^105^ | All women born between 12/1/35 and 12/1/45 (n=10,766), invited to screening 12/1/95; data drawn from population register | Study says ages 55–64 but taking definition, ages should be 60–70 | | | | - Any type UI in continent group=53.3%; - Any type of UI in incontinent group=93.8%; - Estimated overall prevalence of 66%; - Any type UI defined as urge, stress, nocturnal or leakage without reason; - Incontinence by type:
Cross sectional survey | 6,917 screened; 2,213 admitted they were incontinent | 100% women | | | | Incont | Cont | Calc. | Overall
No Adjustment for confounding factors | 1,500 randomly drawn from 2,213 incontinent and 1500 randomly drawn from 4704 not admitting to incontinence | No figures on race/ethnicity | | | | Urge | 79.2% | 36.2% | 57.6%
Purpose: | Incontinence as self reported urinary leakage which causes a social and/or hygienic problem | Lund area of Sweden | | | | Stress | 85.1% | 41% | 63.0%
To investigate the prevalence of storage and emptying LUTS in women reporting UI or continence; the perceived bother induced by UI, and investigate a possible cut off above which most women perceive their leakage frequency as bothersome | BFLUTS survey then administered to both groups; response rate 89%- (1,336/1,500) from incontinent group and (1,346/1,500) from continent group | Excluded subjects with incomplete data | | | | Noc | 13.1% | 3% | 8.0%
| | | | | | No cause | 34% | 7.4% | 20.7%
| | | | | | - Amount by Frequency
| | | | | | | <1/wk | 2–3/wk | Daily | Several × qd
| | | | | | Drops | 74.2% | 87.2% | 82.2% | 65.3%
| | | | | | Dribble | 1.9% | 6.9% | 11.5% | 19.4%
| | | | | | Soak | 0.3% | 1.2% | 0.6% | 11.7%
| | | | | | Run down legs | 0.2% | 0.3% | 1.3% | 3.1%
| | | | | | Problem (calc) | 57.8% | 86.7% | 96.2% | 99.0%
Swanson, 2005 ^106^ | Survey mailed to 100% (362/362) of small family practice and to random sample of 62.4% (720/1,553) in second practice (list of women generated from roster and/or billing databases) | - Ages 45–81+; - 100% women; - No figures on race/ethnicity; - Practices in Hamilton Ontario; - Excluded subjects with incomplete data | | | | Prevalence | Problem
Cross sectional survey | UI and type defined by yes to 1 of 2 questions: 1) during past month have you ever experienced urine loss (wet yourself) when coughing, laughing, or doing some other activity? (stress incont) 2) During the past month have you ever had to pee and then wet yourself before getting to the toilet? (urge incont.); if answered yes to both questions, defined as mixed incontinence | | | | | Any UI = 51.3% (311/606) | 35.7% (111/311)
Adjusted for age | Negative answer to 3^rd^ question defined continent women: Is wetting yourself a problem that interferes with your day-to-day activities or bothers you in other ways? | | | | | Stress UI = 17.5% (106/606) | 17.9% (19/106)
Purpose: To examine age specific prevalence and correlates of UI and its subtypes among community dwelling women | Response rate: 61.1% by author report (606/992); calculated rate is 56% (606/1082); 90 returned undelivered, 115 not participating, and 271 not returned at all | | | | | Urge UI = 7.4% (45/606) | 20.0% (9/45)
| | | | | | Mixed UI = 26.4% (160/606) | 51.9% (83/160)
| | | | | | CI = 95%
| | | | | | No breakdown by severity
Rohr, 2005 ^107^ | Study population identified from Central Person Registry participating in 3 studies using same survey, invited via letter (n=6,369); randomly sampled 45–68 year olds from the Longitudinal Study of Danish Twins (n=2075); 70–94 year olds from the Longitudinal Study of Aging Danish Twins (N=2400) and The 1905 Cohort Study of Danes (n=1,320) from 1998. | Age ≥45 | | | | Incontinence by type:
Cross sectional study using in person interviews | Response rate: 91% (5,795/6,369); original studies' response rate varied between 63–83% | 100% women | | | | | All UI | Stress | Urge
No Adjustment for confounding factors | Interviews in home by trained interviewers; 3 attempts to contact Incontinence self reported as leaking >1 time during the past month with either physical exertion, strong urgency or both | No figures on race/ethnicity | | | | All age (calc) | 32.6% | 24.5% | 19.6%
Purpose: | | Danish subjects only | | | | | (1,857/5,699) | (1,401/5,711) | (1,118/5,711)
To describe the prevalence of urge and stress incontinence and find simple clinical characteristics that are useful in general practice for identifying women with a high probability of UI | | Excluded 574 subjects unable to complete the interview without a proxy; incomplete data for any questions | | | | By Age:
| | | | | | <60 | 20.1% | 15.5% | 9.1%
| | | | | | | (268/1,336) | (207/1,336) | (122/1,337)
| | | | | | 60–80 | 29.8% | 21.8% | 16.4%
| | | | | | | (677/2274) | (496/2279) | (374/2279)
| | | | | | ≥80 | 43.7% | 32.4% | 8.0%
| | | | | | | (912/2089) | (679/2096) | (622/2095)
| | | | | | Asked about frequency, no results given
| | | | | | Did not ask about impact
Ruff, 2005 ^108^ | Population: Convenience sample of 500 college educated women from prestigious AA women's group of attending a conference | Ages 19–82 | | | | Incontinence (n=85):
Cross sectional survey | Response rate: 47% (233/500) | 100% women | | | | All ages/all types 37.6% (85/233)-calc: 36.5%
Purpose: | Inclusion criteria: membership in the organization, attendance at 1 of the conferences sponsored by the organization and willingness to participate in the study | 100% African Americans | | | | Stress | 76% | (63/83)
To examine prevalence and risk factors of UI | Incontinence based on self report answers to Incontinence Screening Questionnaire (Romanzi & Blaivas, 1997) | Unknown residency-presumed US | | | | Urge | 84% | (70/83)
To determine most commonly seen types of incontinence in healthy African American women | Incontinence defined as leaking urine or losing control of urination when subject did not want to | No exclusion criteria given | | | | Mixed | 68% | (58/85)
| | | | | | By severity (n=83):
| | | | | | | Stress | Urge
| | | | | | Never | 24.1% (20/83) | 15.7% (13/83)
| | | | | | Few x's/yr. | 41.0% (34/83) | 38.6% (32/83)
| | | | | | Few x's/month | 13.3% (11/83) | 15.7% (13/83)
| | | | | | Few x's/wk | 10.8% (9/83) | 18.1% (15/83)
| | | | | | Daily | 10.9% (9/83) | 12.0% (10/83)
| | | | | | By pad usage (n=48):
| | | | | | None | 39.7% (23/48) | calc: 47.9%
| | | | | | 1 pad | 29.3% (17/48) | calc: 35.4%
| | | | | | 2 pads | 10.3% (6/48) | calc: 12.5%
| | | | | | 3 pads | 3.4% (2/48) | calc: 4.2%
| | | | | | 4+ pads | 17.2% (10/48) | calc: 20.8%
| | | | | | Four women reported soaked pads at noc
| | | | | | Ten women reported soaked pads during day
| | | | | | By bother rating (n=78):
| | | | | | No bother | 15.4% (12/78)
| | | | | | 1–2 | 39.7% (31/78)
| | | | | | 3–4 | 18.3% (14/78) | calc: 17.9%
| | | | | | 5–6 | 9.2% (7/78) | calc: 9%
| | | | | | 7–9 | 17.9% (10/78) | calc: 12.8%
| | | | | | 10 (intolerable) | 5.3% (4/78) | calc: 5.1%
| | | | | | Duration also given in article
Lifford, 2005 ^109^ | Study population: Nurses Health | - Aged 50–75; - 100% women; - No figures on race/ethnicity; - Nurses in US; - Excluded 13,909 women who had leakage 1–3 times/month; also women with type I diabetes, gestational diabetes or those who self-reported DM but did not provide diagnostic details excluded from analysis | | | | Prevalence: 17.4% (14286/81,845)
Cross sectional study using survey methodology embedded in prospective cohort design | Study cohort established in 1976 responding to UI items in the biennial questionnaire in 1996 (n=83,569) | | | | | Severity:
Adjustment for age, duration and complications of DM | Sample size after exclusions 81,845 | | | | | - 10.9% (1555/14,286) leaked enough to wet outer clothing or floor; - 21.8% (17,829/81,845) <1x/month, a few drops; - 9.4% (7672/81,845) <1x/month, wet underwear or more
Purpose: To evaluate the association between type II diabetes and development of urinary incontinence in women | Response rate: unknown | | | | | Did not ask about impact
| 3 attempts to contact, then shortened questionnaire sent
| Incontinence and diabetes based on self report
| Incontinence as leaking at least weekly, severe incontinence as weekly leaking of sufficient quantity to wet the underwear
Fritel, 2005 ^110^ | Population: GAZEL cohort 45–50 years between 1990–1996 100% sample sent a questionnaire on UI and obstetric symptoms in 2000 (n=3114) | - Ages 49–61; - 100% women; - Unknown race; - French workers of national power company; - No exclusion criteria given | | | | (n=2625)
Cross sectional self reported survey | Response rate: 84% (2625/3114) | | | | | Stress UI: | 68.4% (1796/2625)
Purpose: | Used answers from questionnaire developed for GAZEL study | | | | | Severe SUI: | 15% (386/2625)
To examine prevalence of stress UI | Stress UI defined as urine leak when physically active, coughing or sneezing in the previous four weeks | | | | | By severity:
To examine potential obstetric risk factors of UI | Severely incontinence women leaked often or all the time | | | | | | Stress
| | | | | | Never | 32% (829/2625)
| | | | | | Occasionally | 28% (724/2625)
| | | | | | Sometimes | 26% (686/2625)
| | | | | | Often | 10% (260/2625)
| | | | | | All the time | 5% (126/2625)
| | | | | | Whether a problem in severe cases (n=386):
| | | | | | Not a problem | 1% (3/386)
| | | | | | Slight problem | 21% (81/386)
| | | | | | Quite a problem | 24% (94/386)
| | | | | | Serious problem | 53% (206/386)
Oskay, 2005 ^111^ | From latest national census: | - Ages 50–65+; - 100% women; - No figures on race/ethnicity; - Lived in Istanbul, Turkey; - Excluded subjects with surgically induced menopause or those with presenting complaint of UI | | | | Any type UI =68.8% (344/500)
Cross sectional in person survey | Purposive/categorical sampling of 500 women, each representing 1/10,000 women in the 4 age groups on the census (50–54 n=126, 55–59 n=113, 60–64 n=101, 65+ n=160), seen at health center for problems other than UI or with a person coming to the clinic | | | | | - Stress UI=37.2% (128/344); - Urge Incontinence=32.3% (111/344); - Mixed Incontinence=30.5% (105/344)
No Adjustment for confounding factors | Inclusion criteria: Post-menopausal (no period in the last year) | | | | | Frequency (n=500):
Purpose: To determine the prevalence of urogenital complaints in post-menopausal women aged 50 and over | SUI as involuntary urinary loss precipitated by coughing, sneezing or physical exertion; Urge incontinence as involuntary urinary loss proceeding the urge to void or uncontrollable voiding with little or no warning; Mixed incontinence as the presence of both stress and urge incontinence Serious incontinence as continuous use of pad | | | | | <1x/mo | 18.2 % (91/500)
| Developed their own survey | | | | | >2x/mo | 30.8% (154/500)
| No response rate given-appears 100% | | | | | Serious UI | 19.8% (99/500)
| | | | | | Weekly incontinence (n=344):
| | | | | | <1x/wk | 33.2% (114/344)
| | | | | | Weekly | 17.7% (161/344) | calc: 46.8%
| | | | | | Once daily | 8.4% (20/344) | calc: 5.8%
| | | | | | >1x/day | 22.7% (78/344)
| | | | | | Severity (n=344):
| | | | | | Drops | 41.6% (143/344)
| | | | | | Wets underwear | 36.9% (127/344)
| | | | | | Wets dresses | 14.5% (50/344)
| | | | | | Urine leaks through legs (runs down legs) | 7.0% (24/344)
Melville, 2005 ^112^ | Population: 6,000 women 30–90 years drawn from claims, and pharmacy data from Group Health Cooperative members (n=550,000), stratified by decade of age with over sampling of women in younger decades | - Ages 30–90; - 100% women; - No figures on race/ethnicity, just a non-white category; - Women living in Washington state; - Excluded subjects that were unable to be located, had dis-enrolled, had paralysis, mental or physical incapacity to complete a written questionnaire or a current UTI | | | | Prevalence:
Cross sectional survey using mailed questionnaire | UI as by leakage of any amount that occurred at least monthly | | | | | All UI/all ages: 42% (1458/3438)
Adjusted: for age | - SUI: leaking or loosing urine during activities such as coughing, laughing or walking; - Urge UI: leaking or losing urine associated with an urge to urinate so strong and sudden that the participant could not reach the toilet fast enough; - Mixed: if answered affirmatively to both sets of symptoms | | | | | SUI: 33% (480/3438)
Purpose: To determine the prevalence and severity of UI and the factors associated with this condition in a population based sample of women aged 30–90 | Sandvik Severity Index used to characterize degree of incontinence; QOL measured by Incontinence QOL Instrument (I-QOL) and severity by Patient Incontinence Severity Assessment | | | | | Urge UI: 13% (187/3438)
| Response rate: 64% (3536/5531); actual analysis on 3,438-calc: 62% | | | | | Mixed UI: 50% (732/3438)
| | | | | | Severity (no n given):
| | | | | | No UI: 58%
| | | | | | Slight UI: 9%
| | | | | | Moderate UI: 15%
| | | | | | Severe UI: 18%
| | | | | | Frequency of UI (no n given):
| | | | | | Monthly: 44%
| | | | | | Weekly: 30%
| | | | | | Daily: 26%
Homma, 2005 ^113^ | Randomly selected using a 2 stage randomization process in proportion to the numbers of households. | Age: 40–100 (Mean: 61) | | | | Prevalence:
Cross-sectional | Response rate: 45% (n=4,570) | Gender: Male and female | | | | Overall (Urge incontinence): 6.4%
Adjusted by: | Data source: Self-reported mailed questionnaires | Race: Not reported | | | | Male: 6%
Age, Gender, Parity | Incontinence as, “Urgency with urge incontinence.” | Ethnicity: Not reported | | | | Female: 7%
Functional status | | Residency: Japan
General health condition
Co morbid diseases
Level of evidence: III
Jorgensen, 2005 ^114^ | Selected from all in the municipality of Tromso including those that had suffered stroke and controls. | Age: 24 and older | | | | Prevalence: | By Gender:
Cross-sectional | Response rate: 64.5% (213 stroke patients, 242 age-matched controls) | Gender: Male and Female | | | | | Male: | Female:
Adjusted by: | Data source: Self-administered questionnaires and clinical evaluation | Race: Not reported | | | | Controls: | 12% | 32%
Age, Gender | Incontinence as, “Involuntary loss of urine.” | Ethnicity: Not reported | | | | Stroke survivors: | 21% | 35%
Health status, Medical history | | Residency: Norway | | | | By severity - “More than a little:”
Drug use, Alcohol consumption | | | | | | | Male: | Female
Smoking | | | | | | Controls: | 1% | 9%
Level of evidence: III | | | | | | Stroke survivors: | 6% | 18%
Jumadilova, 2005 ^115^ | Population: 200,000+ residents of eligible NH nationwide | Subjects: =29,645 | | | | UI prevalence prior to exclusions for bowel incontinence: 58% (33, 415/57,596
Design: retrospective, cross sectional secondary data analysis | Sample: All residents of any home in the US if admitted to eligible home and rec'd care between 1/2/02 and 12/31/03 (n=87,000) | Women: 63.8% | | | | Of those eligible UI prevalence: 30% (8,995/29,645)
Adjusted: demographics, comorbid conditions, locomotion, incontinence appliances/conditions | Analyzed: 57,596 records | Race: 89.2% white | | | | No breakdown by type, severity or impact on life
Purpose: To provide a descriptive overview of the elderly, nursing home patient population with UI | Data Source: MDS, NH progress notes, care plans, medication and tx records, physician orders, accounts payable/receivable and cost accounting | Resided in US
| Definition of UI: used MDS question H, 1b to classify UI | Excluded n= 27951; if rec'ing hospice care, were comatose or had bowel incontinence during the period as indicated on the MDS
Stothers, 2005 ^116^ | Subjects were selected from pooled population based surveys and Medicare data. | Age: 60+ | | | | Prevalence:
Cross-sectional | Response rate: Not reported | Gender: Male | | | | Overall: 17%
Adjusted by: | Data source: Population based surveys, such as NHANES, as well as Medicare data. | Race/Ethnicity: Non-Hispanic White, Non-Hispanic Black, Mexican-American, Other, Other Hispanic | | | | By age: | By race:
Age | Incontinence was defined as, “Difficulty controlling bladder.” | Ethnicity: Same as above | | | | 60–64: 11% | Non-Hispanic white: 16%
Ethnicity | | Residency: USA | | | | 65–69: 11% | Non-Hispanic Black: 21%
Education | | | | | | 70–74: 19% | Mexican-American: 14%
Income | | | | | | 75–79: 27% | Other race: 33%
Region | | | | | | 80–84: 27% | Other Hispanic: 21%
Special needs requirements | | | | | | 85+: 31%
Level of evidence: III
Tegerstedt, 2005 ^117^ | Population: 8,000 residents 30–79 years, representative of source population (random sample) Response rate: 69% (5,500/8,000) | Subjects: n=5,489 | | | | Overall UI: no figures given
Design: cross sectional mailed survey | Source: validated 5 item questionnaire with weighted scoring giving a total score | 100% women | | | | - SUI: 63.2% (3444/5489; CI 61.9–64.4%); - Urge UI: 50.5% (2756/5489; CI 49.2–51.8%); - Mixed UI: 3.2% (CI 2.7–3.6%)
Adjusted: age and parity | Definition: Do you suddenly feel the urge to go to the toilet and then accidentally leak urine? Do you leak urine when you cough, sneeze of lift heavy objects? | No race/ethnicity figures given | | | | “Frequent” (often) SUI: 8.8% (CI 8.1–9.6%)
Purpose: To estimate prevalence of symptomatic pelvic organ prolapse in urban female population | | Resided in Stockholm, Sweden | | | | “Frequent” (often) Urge UI: 5.8% (5.2–6.5%)
| | Excluded: inconsistencies in age information
| | From updated Swedish population register
Adelmann, 2004 ^50^ | Community UI prevalence sample of a 1998–1999 survey enrolled in a Medicaid managed health plan in 7 county Minneapolis/St. Paul metro area | Characteristics of community and nursing home N=910 | | | | Prevalence of UI in community sample
Prospective cohort | Age 65 above | | Community | Nursing Home | | | Ever/current | Past week UI
| Random sample of 910 persons enrolled in Medicaid health plan. Of this the n= 378 that were eligible due to UI. Sample was further limited to persons based on at least one claim for a doctor's visit and medical chart could be located. n=236 | Women | 82.1% | 79.2% | | Total | 41.6% | 23%
| Nursing home abstraction sample was randomly drawn from Medicaid persons for a total of 480 persons. | Men | 17.9 | 20.8 | | Women | 45% | 25.5
| Interviews face to face in residence. Response rate 59%, cooperation rate 90% Abstraction of medical record at clinics also. | Age in years | | | | Men | 25.8 | 11.7
| Definition - ever/current UI measured by a yes response to questions about trouble holding urine or leaking urine | 65–74 | 50% | 14% | | Age
| | 75–84 | 34.9 | 34.2 | | 65–74 | 34.1 | 17.6
| | 85+ | 15.1 | 51.9 | | 75–84 | 45.3 | 26.2
| | mean | 75.9 | 84.5 | | 85+ | 58.1 | 33.8
| | Race | | | | White | 45 | 25.5
| | White | 69.4 | 93.8 | | Black | 39.8 | 20.3
| | Black | 14.5 | 4.6 | | Other | 30.1 | 16.1
| | Other | 16.2 | 1.7
Andersson, 2004 ^10^ | 3/2000, Life and Health questionnaire sent to 70,000 residents randomly selected from 274,000, who participated in above study; a special section on UI was given to a sample of 15,360 residents 18–79 years. | 7,680 females | | | | Prevalence for UI was 19% when defined as ‘any leakage’ and 7% when defined as ‘at least once a week’
Population based study, cross sectional | Response rate was 64.5% | 7,680 males | | | | 17% with UI reported severe problems that interfered with daily life
Prospective no control mentioned | Postal questionnaire with 12 questions on UI using definitions from ICS | Age | categories
| Stats on weights and calibration and found results were the same | 18–37 | 53.9%
| | 35–52 | 60.3
| | 50–67 | 69.6
| | 65–82 | 72.2
| | Orebro, Sweden
Bogner, 2004 ^11^ | ECA (Epi Catchment Area) program used to sample 3,481 community dwelling adults (African Americans and Whites initially living in area in 1981) selected for this study. 1,920 were contacted (73% of original cohort) including 822 persons ≥50 years who completed info on UI. After exclusions for missing data, 747 were the final sample. | Mean age of study sample was 67.2 64% were women | | | | 19.8% reported UI during the year preceding the interview
Population based longitudinal survey | Cohort ≥50years at followup interview performed 1993-1996. Those ≥65 years were over-sampled | 72.3% White; mean age 68.2±11 | | | | | white(540) | AA(207)
II-2B | GHQ used and self report on UI | 27.7% AA - mean age 64.5±10 | | | | UI | 22.4% | 13%
| UI = “Have you ever had any difficulty in controlling your water, losing your urine or having trouble getting to the bathroom on time?” If any uncontrolled urine loss was reported within the 12 months before the interview, persons were classified as having UI. | | White | Black | | No information on SI, Urge Incon.
| | Diabetes | 14.3 | 6.9
| | Heart trouble | 27.4 | 26.6
| | Arthritis | 51.1 | 56.5
| | Stroke | 8.2 | 7.3
| | Cancer | 14.4 | 6.3
| | MME | 27.6+-2.6 | 25.6+-3.6
| | ADL impaired | 1.9% | 3.9%
| | East Baltimore, MD USA
Corcos, 2004 ^12^ | Population ≥35 years, stratified by census of metro area and by gender. 7,487 persons in the sample base. 53.7% response rate with 3,249 interviews in final sample. | 48.2% men; mean age | 52 | | | 603 persons had wet OAB, dry or mixed 18.5% (14.7% men and 21.3% women)
Prospective cohort. | Investigators developed standardized questionnaire to ascertain OAB and SUI and impact on quality of life. | 51.8% women; mean age | 50.9 | | | Prevalence of wet OAB;
No control mentioned. | Computer assisted telephone interviews conducted in 2 steps: an initial questionnaire evaluated presence of OAB followed by detailed questionnaire completing the assessment. | 82.4% < 65 years. | | | | 2.3% (2% men and 2.6% women)
| Urgency - “In past few months, did you ever feel an urgent need to urinate, to such a point that if you did not immediately go to the bathroom, you risked having an involuntary urine loss or leak?” | 17.6% > 65 years. | | | | Mixed OAB
| | Montreal, Toronto, Vancouver and Edmonton, Canada | | | | 1.2% (3% men and 2.1% women)
| | | | | | Urgency | total | men | women
| | | | | | Every day | 1.5% | 9% | 2.1%
| | | | | | 3–4 times/week | 1.5% | 5% | 2.4%
| | | | | | 1–2 times/week | 3.6% | 2.7% | 4.5%
| | | | | | 4 times/4weeks | 1.9% | 1.3% | 2.4%
| | | | | | ≤3/month | 12.7% | 11.6% | 13.8%
| | | | | | Urgency
| | | | | | 9.4% (15.3% men and 23.3% women)
| | | | | | SUI; 5.9% (.8% men and 10.6% women)
Dallosso, 2004 ^13^ | Part of the Leicestershire MRC Incontinence Study, focused on women ≥40 years living in the community: From a random sample of 20,244 women drawn, 12,565 returned the questionnaire (65% response). | Baseline data compared to those who provided FFQ data - | | | | Prevalence of SUI at baseline was 17.3%
Prospective longitudinal study. | 7,046 completed FFQ sent to 10,852 of above sample (response rate 65%). 1^st^ postal questionnaire mailed Oct 1998 and completed by 7,046 women. 2^nd^ postal questionnaire mailed Oct 1999 and completed by 6,424 women (91% response rate). | Median age 57 vs. 61 | | | | | Prevalence at baseline
II=2B | Excluded: those in residential/nursing homes and those of South Asian origin (5.3% of pop ≥40 years). | Rating of health poorer in baseline after adjusting for age (OR: 1.66; 95% CI 1.51–1.82) | | | | | Total N | SUI cases %
| Used ICS definitions. | More long term health problems in baseline (OR 1.14; 95% CI, 1.05–1.25) | | | | 40–49 | 1,694 | 16.7
| | No difference in reporting SUI (OR: 1.02; CI 95%, .92–1.13) | | | | 50–59 | 1,761 | 19.8
| | Leicestershire, UK | | | | 60–69 | 1,453 | 16.2
| | | | | | 70–79 | 995 | 15.2
| | | | | | 80y + | 321 | 18.1
de Tayrac, 2004 ^31^ | 717 women who had Dargent and Rudigoz technique. | | Vaginal hyst. | Control | | Prevalence (as stated in article)
Case control, retrospective study | 365 (50.9%) returned questionnaires, 449 did not respond. 51 excluded leaving 314 women. | Age | 51.4 | 50.9 | | | Vag hyster % | control %
II-3 | 117 patients who had a vaginal hysterectomy for menorrhagia from Jan 1991 to Dec 2001 and a control group of 116 patients who had conservative treatment. | Parity | 2.1 | 2.2 | | Freq day>8 | 19.7% | 16.4%
*Authors state it was a case control but they had a control group | 197 had hysterectomy for pelvic pain and 117 for menorrhagia. | Menopause | 43.5% | 47.4% | | Noc: day >1 | 5.1 | 6.9
| Self report questionnaire. | Smoking | 17.9% | 17.2% | | Urgency | 62.4 | 54.3
| | Drink>2 L/d | 7.7% | 9.5% | | Qmo | 36.8 | 30.2
| | Hx of uro sxs | 0 | 0 | | Qwk | 19.7 | 12.1
| | France | | | | Qday | 6 | 12.1
| | | | | | UI | 39.3 | 33.6
| | | | | | Use of pads | 15.4 | 12.9
| | | | | | Urge Inc | 20.5 | 13.8
| | | | | | Qmo | 12 | 7.8
| | | | | | Qwk | 4.3 | 5.2
| | | | | | Qday | 4.3 | 0.9
| | | | | | SI | 36.7 | 31.9
| | | | | | Qmo | 18.8 | 16.4
| | | | | | Qwk | 12.8 | 8.6
| | | | | | Qday | 4.3 | 3.5
| | | | | | Age <60 | VH | Control
| | | | | | UI | 41.8% | 33.7
| | | | | | UI | 21.8 | 12.5
| | | | | | SI | 40 | 33.7
| | | | | | Age >60
| | | | | | UI | 28.6 | 41.7
| | | | | | Urge UI | 14.3 | 25
| | | | | | SI | 28.6 | 33.3
Foldspang, 2004 ^51^ | Sample of 6,240 and 6,468 women living in the municipalities of Aarhus and Randers 20–59 years. | C-sec in 12.2% of 1^st^ childbirths. | | | | UI during pregnancy with 1^st^ child 15.6% (2^nd^ birth 18.5%) and 12% of deliveries by c-section for 1^st^ child.
Age stratified random samples | Analysis based on 1,232 women in combined samples who reported their 1^st^ and last childbirth within 13–120 months prior to responding to the questionnaire; minimum f/u period after childbirth was 12months. | Average age - 32.8yrs (20–41). | | | | UI following 1^st^ birth was reported by 26.3% (UI>2wks, 14%; UI >4wks, 9.4%); 2^nd^ birth, 30.5% (UI >2wks, 8.2%, UI >4wks, 5.9%)
II-2A | Self questionnaire mailed Jan–March 1995 and 1998. | 52.1% reported having 2 births or more. | | | | Table I. 1st and 2^nd^ birth postpartum urinary incontinence (PPUI) occurrence* by UI during pregnancy, mode of delivery (cesarean section vs. vaginal childbirth) and childbirth number, in 1232 women. Aarhus and Randers, Denmark, 1995 and 1998 Women: PP UI OR Determinant n (%) (%) OR
| 67.8% responded | Mean age at 1^st^ birth = 27.5yrs and 29.9yrs at 2^nd..^ | | | | 1^st^ birth (n=1,232)
| | Average duration since 1^st^ childbirth was 5.3yrs. | | | | All women 1,232 (100.0) 26.3
| | Denmark | | | | Pregnancy UI
| | | | | | Yes: 192 (15.6) 66.7 8.6 (6.1–12.1)
| | | | | | No: 1,040 (84.4) 18.8 (Reference)
| | | | | | Mode of delivery
| | | | | | Vag: 1082 (87.8) 28.3 2.9 (1.7–4.8)
| | | | | | C- section: 150 (12.2) 12.0 (Reference)
| | | | | | 2nd birth: (n=642)
| | | | | | All women: 642 (100.0) 30.5
| | | | | | Pregnancy UI
| | | | | | Yes: 119 (18.5) 75.6 12.2 (7.6–19.5)
| | | | | | No: 523 (81.5) 20.3
| | | | | | (Reference)
| | | | | | Mode of delivery
| | | | | | Vag: 603 (93.9) 31.3 2.1 (0.9–4.8)
| | | | | | C section: 39 (6.1) 17.9 (Reference)
| | | | | | *PPUI occurring at all. †p<0.10; ‡p<0.001.
| | | | | | Table II. 1st and 2nd (PP UI) occurrence* by mode of delivery; cesarean section (CS) vs. vaginal childbirth (VC)], preceding pregnancy UI (PRUI) and birth number, in 1,232 women.
| | | | | | Pregnancy UI Mode Total no. PPUI (%)
| | | | | | 1st birth (n=1,232)
| | | | | | PRUI | VC | 169 | 68.6
| | | | | | PRUI | CS | 23 | 52.2
| | | | | | No PRUI | VC | 913 | 20.8
| | | | | | No PRUI | CS | 127 | 4.7
| | | | | | 2nd birth (n=642)
| | | | | | PRUI | VS | 113 | 76.1
| | | | | | PRUI | CS | 6 | 66.7
| | | | | | No PRUI | VS | 490 | 21.0
| | | | | | No PRUI | CS | 33 | 9.1
Fritel, 2004 ^52^ | French women from hospital database of 1^st^ birth women who had not previously delivered fetus >22 weeks | Age at delivery (years) | 29.3 (4.4) | | | Circumstances of leakage
retrospective cohort | 307/669 primiparous women who delivered in 1996 in vertex position between 37–41 wks (274 had moved and 88 did not respond) 45.9% response rate. Excluding the women who did not receive the questionnaire (274), response rate was 77.7% | BMI (kg/m2) | 21.3 (2.9) | | | Stress | 89.9 (89)
II-2C | Questionnaire sent by mail 4weeks after delivery asking about SUI before, during and after pregnancy - “Do you have loss of urine during physical exertion, cough or sneeze?” | Birth weight (g) 3240 | 3240 (384) | | | Urge | 64.6 (64)
| UI categorized slight, mode or severe using Sandvik Index. | Labor (h) | 6.2 (2.3) | | | Other circumstances
| | Active 2nd stage (min) | 11.1 (7.5) | | | Frequency of leakage | 22.2 (22)
| | Cesarean section | 10.1 (31) | | | Less than once a month | 41.4 (41)
| | Forceps | 36.2 (111) | | | One to 3 times per month | 29.3 (29)
| | Third-degree tear | 1.3 (4) | | | One to 3 times per week | 11.1 (11)
| | | | | | Everyday | 10.1 (10)
| | | | | | Unknown | 8.1 (8)
| | | | | | Amount of leakage
| | | | | | Drops | 69.7 (69)
| | | | | | Small amount | 23.2 (23)
| | | | | | More | 3.0 (3)
| | | | | | Unknown | 4.0 (4)
| | | | | | Bothered by incontinence
| | | | | | Not at all | 17.2 (17)
| | | | | | A little | 54.5 (54)
| | | | | | Moderately | 15.2 (15)
| | | | | | A lot | 10.1 (10)
| | | | | | Unknown | 3.0 (3)
| | | | | | Use of pads for incontinence
| | | | | | None | 74.7 (74)
| | | | | | One to 6 per week | 16.2 (16)
| | | | | | One or more per day | 4.0 (4)
| | | | | | Unknown | 5.1 (5)
Haltbakk, 2004 ^18^ | 480 Norwegian men at St. Olavs Hospital, Trondheim Norway. Tentative dx of BPH made on 612 pts and from this pool, sample analyzed was 480 (78%). | Mean age of patients was 67 years, SD 10.6 years; median 69 years range 39–9 1years | | | | 37% any leakage
Prospective cohort no control mentioned ?historical control | ICS LUTS questionnaire (ICS-BPH) between 1997-2000. IPSS, SPI and SISI used also. | mean age in incontinent group was 68 years | | | | 12% slight
| UI defined as any involuntary leakage of urine. | | | | | 18% moderate
| | | | | | 3% severe
| | | | | | 4% not possible to classify
| | | | | | 20% experienced at least some bother
| | | | | | 21% drops
| | | | | | 13% small splashes
| | | | | | 1% substantial amounts
| | | | | | 61% of incontinent group had urge incontinence.
| | | | | | 2% had stress incon
| | | | | | 9% had mixed
| | | | | | 28% were unclassified
Holroyd-Leduc, 2004 ^19^ | Community dwelling in US 6506 of 7447 subjects aged 70 and > in the Asset and Health Dynamics Among the Oldest Old study who had complete info on continence status were baseline - outcomes 3 groups- 5,872 nursing home, 5521 ADL decline and 5,509 IADL decline as outcomes | Mean age =/- SD = 77 (range 69–103) | | | | Baseline prevalence for UI was 14.8% (18.5% in women and 8.5% in men)
Population based | Subjects interviewed in 1993 and 1995 | 63% female
Prospective cohort | Blacks, Hispanics and Florida residents were over-sampled | 86% white
Confounders - sex, age, sex, race, smoking, alcohol, BMI, sensory impairment, comorbid disease, depression, cognitive function and baseline dependency. | Overall response rate was 80% | Median number of baseline comorbid medical conditions was 2
II-2A | UI measured “next question might not be easy to talk about, but it is very important for research on health and aging, during the last 12 months, have you lost any amount of urine beyond your control?” | 10% received help with ≥1ADLs and 23% were receiving help in ≥1 IADLS at baseline
| | Pts with UI had more comorbidities (p =.001), higher rate of visual impairment (35% vs. 22.4% p <.001) and hearing impairment (39.7% vs. 30.5% p <.001) more functionally impaired at baseline
Hunskaar, 2004 ^20^ | Postal survey mailed to 29,500 households in 4 countries - France, Germany, UK and Spain (age ≥18yrs) | Mean age | | | | In all, 35% of women reported they had UI in past 30 days
Cross national study, Prospective | 58.1% response rate | France - 44.8 | | | | France - 44%
No control group | 5976 women with UI included in analysis (35% of study pop) | Germany - 59 | | | | Germany - 41%
| Definitions used by ICS; sxs in last 30 days and in last 7 days | UK - 45 | | | | Spain - 23%
| | Spain - 64 | | | | UK - 42%
| | All - 58
Jackson, 2004 ^22^ | 1,017 post menopausal US women a 55–75 years enrolled in HMO and followed for 2 years (1998–2002) inclusion criteria were no natural menstrual cycle in past 12 months (oral estrogen or vaginal estrogen users were excluded), resided in Washington state. Exclusion factors were residential nursing care, restriction to wheel chair, dementia or severe psych disorder, indwelling catheter or intermittent urinary catheter, end stage renal disease requiring dialysis, active malignancy other than skin cancer and chronic antibiotic use. Acute cystitis in past 90 days exclusionary. | Frequency of Exposures at Enrollment and Univariate Risk of Symptomatic Urinary Tract Infection | | | | Accidental leakage of urine in last year
population based | Postvoid residual bladder volume measured using portable ultrasound device. | Characteristic (%) Hazard Ratio (95% Confidence Interval) | | | | No | (34) | 1.0
Prospective cohort; also randomly selected from HMO diabetes registry | 12 month f/u done by 87% and 24mo f/u by 81%. | Complete sample† 1,017 (100) Age (years) | | | | Yes | (66) | 1.6 (0.9–2.7)
II-2A | Primary study outcome was sx cystitis. | 55–59 | 32 | 1.0 | | Type of urinary incontinence in last month
| | 60–69 | 42 | 1.3 (0.8; 2.2) | | None | (41) | 1.0
| | 70–75 | 26 | 1.6 (0.9; 2.9) | | Stress only 174 (17) 19 0.9 (0.5–1.8)
| | Ethnicity | | | | Urge only 106 (10) 20 1.7 (0.8–3.6)
| | White | 87 | 1.0 | | Stress and urge 324 (32) 52 1.4 (0.9–2.4)
| | Other | 12 | 0.6 (0.3; 1.2) | | Postvoid residual bladder volume
| | General health score from SF-36 | | | | <50ml residual | (79) | 1.0
| | 76–100 | (51) | 1.0 | | 50–100ml residual | (10) | 1.1 (0.5–2.2)
| | 51–75 | (37) | 2.0 (1.2–3.3) | | >100ml residual | (10) | 1.6 (0.8–3.2)
| | 0–50 | (12) | 2.6 (1.3–4.8)
| | Smoking history
| | Never | (55) | 1.0
| | Former | (39) | 0.9 (0.5–1.4)
| | Current | (6) | 0.1 (0.02–0.8)
| | Diabetes at baseline
| | No | (79) | 1.0
| | Yes | (21) | 1.9 (1.1–3.1)
| | Diabetes treatment type
| | Not diabetic | (79) | 1.0
| | Diet or pill | (17) | 1.2 (0.7–2.0)
| | Insulin | (4) | 4.7 (2.2–10.3)
| | Accidental leakage of urine in last year
| | No | (34) | 1.0
| | Yes | (66) | 1.6 (0.9–2.7)
| | Type of urinary incontinence in last month
| | None | (41) | 1.0
| | Stress only | 174 | (17)
| | | 19 | 0.9 (0.5–1.8)
| | Urge only | 106 | (10)
| | | 20 | 1.7 (0.8–3.6)
| | Stress and urge | 324
| | | (32) 52 | 1.4 (0.9–2.4)
| | Postvoid residual bladder volume
| | <50ml residua
| | | (79) | 1.0
| | 50–100ml residual
| | | (10) | 1.1 (0.5–2.2)
| | >100ml residual
| | | (10) | 1.6 (0.8–3.2)
| | History of hysterectomy
| | No | (69) | 1.0
| | Yes | (31) | 1.2 (0.8–2.0)
| | History of kidney stones
| | No | (90) | 11.0
| | Yes | (5) | 2.4 (1.2–4.9)
| | History of bladder or urinary surgery
| | No | (90) | 1.0
| | Yes | (10 | 1.6 (0.9–3.0)
| | Parity (no. of full-term pregnancies)
| | 0 | (14) | 1.0
| | 1–3 | (63) | 1.3 (0.7–2.5)
| | >4 | (23) | 2.2 (1.1–4.3)
Jackson, 2004 ^21^ | Of 1,584 white and black women 70–79 years at 2 clinical sites in Pittsburg and Memphis recruited, 1,558 answered the questions. | Mean age 73.5 | | | | 9.6% reported daily UI
cross sectional analysis, longitudinal study | Enrollment Limited to those who reported no difficulty walking 1/4mile, climbing 10 steps or performing ADLs | 49% were black | | | | 11.6% weekly UI
II-2A | Questionnaires - in the past 12 months, have you leaked even a small amount of urine? How often have you leaked? | 20% diabetes | | | | 24% less than weekly UI
| | 64% arthritis | | | | (note abstract reports a different weekly number but text reports above number)
| | 55% hypertension | | | | of those with weekly UI
| | 27% white reported weekly UI vs. 14% black | | | | Urge UI was 42% and SI was 40% and incontinence unrelated to stress or urge was 14%
Johnson, 2004 ^23^ | Men from the Prostate Cancer Outcomes Study dx with primary prostate cancer between Oct 1994–Oct 1995 | 1,433 men RRP | | | | Wt % for men with RRP
Long term cohort, | Residents of LA, King County, Washington, states of Connecticut, NM, UT, between ages of 60–89yrs in King County and younger than 90 in others. | 642 men received Radiotherapy | | | | | NHW | AA | Hispanic
Prospective study of RRP vs. Radiotherapy | Self questionnaire at 6, 12, 24 and 60 months after diagnosis and medical record review at 12 and 60 mos. 11,137 men identified in registries; 5672 randomly selected, letters sent to 4,736(83.5%) of selected cases. Total of 3,533 men(62.3%) completed 6 and 12mo were included in f/u cohort. | RRP group - wt % by race | | | | Level of urinary control baseline
II-2B | 1433 men had RRP completed 6mos | | NHW | AA | Hispanic | Total control | 87.9 | 86.6 | 80.5
| 1178 did 24 months (82.2%) | Arthritis | 33.3 | 38.6 | 35.8 | Occ leakage | 8.8 | 9.5 | 11.2
| 1109 did 60mos (77.4%) | Diabetes | 11.1 | 29.5 | 17.2 | Freq leakage | 2.1 | 2 | 6.5
| For Radiotherapy - urinary problems not reported | COPD | 7.5 | 6.6 | 5.4 | P = | | .77 | .29
| Questionnaire also translated into Spanish and interview conducted in Spanish when necessary. | HF | 4.9 | 2.1 | 4.4 | 6months
| | CVA | 2.6 | 2.5 | 3.3 | Total control | 22.7 | 27.6 | 28.9
| | HTN | 37.3 | 54 | 37.5 | Occ leakage | 52.1 | 44.2 | 40.8
| | MI | 7.9 | 4 | 4.2 | Freq | 22.6 | 23.4 | 26.7
| | Age at dx | | | | P = | | .57 | .83
| | <60 | 27.5 | 38.6 | 23.4 | 12 months
| | 60–64 | 26.8 | 26.1 | 30 | Total control | 33.1 | 38.5 | 37
| | 65–75 | 41.9 | 32.9 | 45.5 | Occ leakage | 50.2 | 51.4 | 46.9
| | >/=75 | 3.8 | 2.4 | 1 | Freq | 15.6 | 9 | 14.9
| | | | | | P= | | .24 | .26
| | | | | | 24 months
| | | | | | Total control | 38.2 | 41.9 | 35.2
| | | | | | Occ leakage | 50.2 | 45.1 | 53
| | | | | | Freq | 9.8 | 11.1 | 11.3
| | | | | | P = | | .86 | .38
| | | | | | 60 months
| | | | | | Total control | 30.8 | 49.3 | 32.8
| | | | | | Occ leakage | 53.7 | 39.7 | 47.4
| | | | | | Freq | 14.3 | 10.4 | 18.7
| | | | | | P= | | .01 | .36
Lagergren, 2004 ^24^ | Subjects from Skane, Karlskrona, Kungshomen and Nordanstig from ≥65 years starting in 2001 to 3/2004. | Men | 3,052 | | | Severe UI-;
National, longitudinal, multi-purpose study in Sweden (SNAC). Study consisted of two parts - population part and the care/service part. | Total pop of SNAC 17,044; baseline 8,627 targeted persons 7,518 sampled. | Women | 4,465 | | | Ordinary homes - 15%
II-2A | 16–25% received public care. | Total | 7,518 | | | Special accom - 44%
| F/U every 6 yrs beginning at age 66. | 12% 65–79yrs old, 6% >80yrs | | | | Total 31%
| Combo of interviews and questionnaires | Avg age 85 compared to avg age in Sweden 83
Moorthy, 2004 ^118^ | Subjects randomly selected from men visiting urology clinics in 11 Asian countries. (n=2,369) | Age: ≥18 years | | | | Prevalence (Urge incontinence):
Cross-sectional | Response rate: Not reported | Gender: Male | | | | Overall: 13%
Adjusted by: Age, Occupation, Income Family history Place of residence | Data source: Self-administered questionnaires | Race: Not reported
Level of evidence: III | Incontinence as, “Urgency with urge incontinence.” | Ethnicity: Asian
| | Residency: China, Hong Kong, India, Indonesia, Philippines, Singapore, Korea, Thailand, and Taiwan.
Ozerdogan, 2004 ^29^ | 625 women ≥20 years, living in 4 different cities in Turkey. 1/4 resided in rural area. 1/5 gave birth at least ≥4 times and most were vaginal deliveries (25%). Illiteracy rate 9.4% | Age distribution | | | | Prevalence of UI was 25.8%
Cross sectional | Questionnaire and I-QOL Rare - UI <1 time/month. Reg - UI >2 times/month Serious - continuous use of sanitary protection. SI and Urge defined as usual definitions. | 20–29 - 26.4% | | | | Rate of rare UI was 9.3%, serious and Regular | 16.5%
Prospective study. | | 30–39 years - 22.6% | | | | SI in women with UI was | 42.9%
II-2A | | 40–49 years - 18.7% | | | | Urge was | 27.3%
| | 50–59 years - 13.4% | | | | MI was | 29.8%
| | 60–69 years - 11.7% | | | | Prevalence of SI was greatest before 50 yrs of age while urge incontinence.
| | ≥70 years - 7.2% | | | | MI dominated in women ≥50 yrs.
| | 50% BMI | >25.0% | | | Prevalence increased in diabetes, neurological and recurrent UTI.
| | Smokers | 25.0% | | | Smoking, HRT menopause did not have an impact on prevalence.
| | Recurrent UTIs | 19.0%
| | Diabetes | 6.6%
| | COPD | 7.5%
| | Neurological disorders | 11.2%
Schytt, 2004 ^30^ | After childbirth at 593 clinics 5,550 women booked appts during recruitment time, 4,500 eligible, 3,191 consented. Three questionnaires: 1^st^ at baseline (n=3,061), 2^nd^ mailed 6–8 weeks after the birth(n=2,762) and 3^rd^ 1 yr after birth(n=2563). Total 2,450 completed all three. Study sample was 2,390 women after exclusions. | Average gestation: | | | | 21.7% sxs of SI at one year
Prospective, longitudinal cohort | Women were asked to recall any sxs of UI during and after pregnancy. | 1^st^ quest - 16 weeks, | | | | Prevalence
II-2A | Selected data from a National Swedish survey investigating physical and psychological assessment of childbirth May and Sept 1999 and January 2000 antepartal visits | 2^nd^ - 10 weeks post, | | | | Primi | Multi | Vaginal | C-Section
| Excluded miscarriages, non-Swedish speaking, and women from nonparticipating clinics, delivery of twins | 3^rd^ - 1 year and 2 weeks. | | | | 18.4% | 24.3% | 23.4% | 10.6%
| | Avg age at recruit - 29.5 years
| | Primiparas - 44%
| | Multiparas - 56%
| | 79.2% had vaginal delivery
| | 13.4% had c-section
| | Sweden
Stenzelius, 2004 ^54^ | Subjects were selected and mailed a questionnaire from a randomized, age-stratified sample of persons ≥75 years living in a southern part of Sweden. Response rate: 52.8% (n=4,277) | Age: 75 and above | | | | Prevalence by age group and severity:
Cross-sectional | Data source: Self-reported postal questionnaire | Mean: 83.7 (SD: 5.69) | | | | Male | 75–79 | 80–84 | 85–89 | 90+
Adjusted by: Age, Gender, Quality of life, Occupation, Economy, Living condition, Need of help, Satisfaction with children contact, and problems with Communication, Mobility, Elimination, Digestion, Breathing and circulation Psychosocial problems Other type of pain | Incontinence as a yes to the question, “Have you had problems controlling urine in the last 3 months?” | Gender: Male and Female | | | | A little | 26 | 23.6 | 27 | 20.9
Level of evidence: III | | Male: 38.4% | | | | Very much | 5.2 | 8.9 | 16.6 | 21
| | Female: 61.6% | | | | Total | 31.2 | 32.5 | 43.6 | 41.9
| | Race: Not reported | | | | Female | 75–79 | 80–84 | 85–89 | 90+
| | Ethnicity: Not reported | | | | A little | 23.2 | 26.8 | 25.9 | 32.3
| | Residency: Community dwelling and special accommodations residents in Southern Sweden. | | | | Very much | 10.1 | 13.5 | 19.1 | 23.5
| | | | | | Total | 33.3 | 40.3 | 45 | 55.8
Vandoninck, 2004 ^55^ | Dutch women from Urepik (Uro Epi in Europe and Korea)study in the community | During the past month: | % | | | Mean age 57 (29–79)
Age stratified | In 1999, a national postal questionnaire survey of 1,460 spouses of 1,771 men. 1,071 returned - 73 response rate | How often have you leaked urine? | | | | 34% minimal UI. 12% severe
Prospective cohort for men in the original study. | UI assessed by total score on short UI specific questionnaire - 3 groups - no sxs score (0–2); minimal (3–6) and severe (7–14). In addition, self reported UI was calculated conforming to ICS standard definitions. | 0) Never | 54.5% | | | Self report UI was 40%
Mentions sampling wts upon the ratio of # of women in each age group in the sample to # of women in the age group in population. | “Do you ever have involuntary urine loss?” | 1) ≤1/week | 19.6% | | | 38% consulted physician
| QOL also used | 2) >1 but <3 times/week | 10.0% | | | Mean parity 2.6
| | 3) >3 times/week | 6.0% | | | 13.5% women were childless
| | 4) Nearly always | 8.6% | | | 68% SUI
| | If you experienced urine loss, how much did you leak?
| | 0) I never leak | 50.2%
| | 1) Some drops | 32.2%
| | 2) A small stream | 11.4%
| | 3) Protection material or clothes soaking wet | 4.9%
| | 4) Leaking through pads or clothes | 0.3%
| | How often do you use protection material
| | 0) Never | 68.1%
| | 1) Occasionally | 21.4%
| | 2) Nearly always | 3.9%
| | 3) Always | 5.8%
| | Did you lose urine on coughing or sneezing?
| | 0) Never | 31.1%
| | 1) Occasionally ) | 45.0%
| | 2) Nearly always | 13.5%
| | 3) Always | 9.3%
Teunissen, 2004 ^119^ | Subjects selected from patients ≥60 in 9 general practices in the Nijmegen | Age: 60 years and older | | | | Prevalence:
Cross-sectional | Monitering Project, Netherlands. | Gender: Male and Female | | | | Overall=19%, Male:=9%, Female=29%
Adjusted by: | Response rate: 88% (n=4,650) | Male: 46% | | | | By Age and Gender:
Age | Data source: Self reported, mailed questionnaires. | Female: 64% | | | | Male:
Sex | Incontinence was defined as, “Involuntary loss of urine twice or more per month.” | Race: Not reported | | | | Age | Prevalence % | 95% CI
Level of evidence: III | | Ethnicity: Not reported | | | | 60–64 | 5 | 3.6–6.8
| | Residency: Netherlands | | | | 65–69 | 6 | 4.3–8.2
| | | | | | 70–74 | 8 | 5.6–11.3
| | | | | | 75–79 | 14 | 10.2–18.9
| | | | | | 80+ | 21 | 14.7–28.9
| | | | | | Total | 9 | 7.4–10.9
| | | | | | Female:
| | | | | | Age | Prevalence % | 95% CI
| | | | | | 60–64 | 22 | 19.2–25.1
| | | | | | 65–69 | 26 | 22.6–29.7
| | | | | | 70–74 | 29 | 25.1–33.3
| | | | | | 75–79 | 36 | 30.9–41.5
| | | | | | 80+ | 38 | 32.4–44.2
| | | | | | Total | 29 | 27.2–30.9
Araki, 2003 ^120^ | Subject selection: Using the I-PSS questionnaire with an additional question on urinary incontinence, LUTS in all outpatients 40 years or older were examined from June 2001 to December 2002. | Men and women aged 40–92 years | | | | Women:
Cross-sectional | Exclusion criteria: Concurrent urinary tract infection, psychological disease, medication with anti-cholinergic agents, alpha-receptor blockers, anti-androgens, diuretic agents or other drugs that may possibly affect urinary function. | Japan | | | | UI Prevalence: = 40%
Level of evidence: III | Response rate: 550/1201= 46% | | | | | Severity: Moderate to Severe UI
| Data source: Clinic based | | | | | 40–49 years (24%)
| Definition: The severity of symptoms was defined by the total I-PSS as mild—0 to 7, moderate—8 to 19 and severe—20 to 35. By an additional question urinary incontinence was scored from 0 to 3 as 0— not at all, 1—wet underwear, 2—wet clothes and 3— a large amount. | | | | | 50–59 years (24%)
| | | | | | 60–69 years (39%)
| | | | | | 70–79 years (45%)
| | | | | | 80 yrs or older (50%)
| | | | | | Men:
| | | | | | UI Prevalence = 24%
| | | | | | Severity: Moderate to Severe
| | | | | | 40–49 years (30%)
| | | | | | 50–59 years (38%)
| | | | | | 60–69 years (44%)
| | | | | | 70–79 years (52%)
| | | | | | 80 years or older (58%)
Boyle, 2003 ^121^ | Subject selection: A standard questionnaire asking about frequency and amount of urine loss, use of pads and stress incontinence, was used to measure the prevalence of UI among men in four countries. | Men | | | | Prevalence: Mild-Severe UI
Level of evidence: II-2 | 4979 men responded to the questionnaire. | Age: 40–79 yrs | | | | UK= 14.4%
| Definition: UI was assessed using the total score from four questions which asked about frequency and quantity of urinary leakage, the use of pads and stress incontinence. The score was 0–14, with high scores indicating the presence of a problem. Groups were defined as 0–2 (none), 3–6 (mild), and 7–14 (severe). | Boxmeer, The Netherlands; Auxerre, France; Birmingham, UK; and Seoul, Korea). | | | | Netherlands=16.2%
| | | | | | France=7.3%
| | | | | | Korea=4.3%
| | | | | | Age related prevalence: 40–49yrs
| | | | | | UK=14.4%
| | | | | | Netherlands=12.7%
| | | | | | France= 5.2%
| | | | | | Korea= 1.9%
| | | | | | 60–69 years
| | | | | | UK=13.7%
| | | | | | Netherlands=22.6%
| | | | | | France= 9.2%
| | | | | | Korea= 8.0%
Burgio, 2003 ^122^ | Subject selection: Participants: women, ages 14 to 42 years, who had obstetrical deliveries. The women were interviewed on postpartum day 2 or 3 and by telephone 6 weeks, 3 months, 6 months, and 12 months postpartum. | Women | | | | Prevalence: UI
Level of evidence: II-2 | Definition: When obtaining the continence history, the interviewer asked, “Have you ever experienced any difficulty controlling urination? Have you ever had any accidental loss of urine, even a small amount?” A negative response was followed by rephrasing the question, “Have you ever wet yourself?” Those who acknowledged any incontinence were asked several questions about onset, course, when it occurred, under what circumstances, and the frequency and volume of urine loss. | Age:14 to 42 years (mean, 28.6 years; median, 29.0). | | | | Intra-partum =59.6%
| | Caucasian:82.4%, | | | | 6 weeks =11.36%
| | Black: 16.1% | | | | 3 months =9.32%
| | Hispanic/Asian:1.2% | | | | 6 months =10.51%
| | USA | | | | 12 months =13.25%
Chen Gin-Den, 2003 ^123^ | Subject selection: 1,581 women sampled (2.92% of registered female residents aged 20 years and older), | Age: | | | | Prevalence
Level of evidence: II-2 | Response rate: 1,253 (79.1%) women were successfully interviewed by using the Bristol Female Urinary Tract Symptoms Questionnaire and the Questionnaire of Impact index regarding the impact on quality of life. | Mean= 43.2yrs | | | | Stress UI:18%
| Definition: Urinary incontinence as involuntary urine leakage occurring during physical activities that cause stress or an increase in the intra-abdominal pressure and was considered by the participant to be a hygienic or social problem. | Taiwan | | | | Urge UI:18.6%
| Severity of UI was classified as: Grade 1 is defined as mild leakage with moderate stress, no protection is needed. Grade 2 is moderate leakage with moderate stress, and protection is needed with excessive activity. Grade 3 is severe leakage with mild stress, and constant protection is required except at rest. Grade 4 is incontinence at rest, and in need of constant protection. | | | | | Mixed UI:17.1%
| Urge incontinence was defined as involuntary urinary loss preceded by the urge to void or uncontrollable voiding with little or no warning. | | | | | Women who were elderly, menopausal, had vaginal deliveries, higher BMIs, parities >2, symptoms of uterovaginal prolapse, a history of diabetes or hypertension were significantly predisposed to an overactive bladder.
| Overactive bladder was defined as having symptoms of frequency and urgency, or nocturia, with or without urge incontinence. Women who had both stress and urge incontinence were defined as having mixed incontinence. | | | | | In multivariate models, previous gynecologic surgery (OR, 2.0; 95% CI, 1.1, 3.7), parity >2 (OR, 2.0; 95% CI, 1.1, 3.8), a history of diabetes (OR, 3.3; 95% CI, 1.5, 7.6), and symptoms of uterovaginal prolapse (OR, 32.9; 95% CI, 12.5, 87.1) are the potential risk factors for Stress UI. Overactive bladder is only associated with symptoms of uterovaginal prolapse (OR, 21.3; 95% CI, 7.8, 58.2).
| | | | | | Overall, the women suffering from these three types of urinary incontinence reported that they worried about smelling of urine (65.4%), wetting their clothes (68.2%), pad or towel leakage (45.8%), and exposure of pads or towels (43.0%). At least one third of the women believed that urinary incontinence limited their daily activities, including family life (31.8%), social activities (32.7%), outings for pleasure (50.5%), and changed their interests or hobbies (48.6%). Approximately 19% of the women with urinary incontinence reported an impact of this symptom on their sexual life. The reasons for the restriction of social activities were due to worrying about wetting or leakage (60.8%) and no toilet facilities available (60.8%). The study also found that only 27.1% of the women sought medical attention for their symptoms.
Chen Yi-Ching, 2003 ^124^ | Subject selection: Women from a stable community located in central Taiwan. | Age | | | | Prevalence of Urge UI
Level of evidence: II-2 | 1,584 (2.92%) were randomly sampled, 1,253 (79.1%) were successfully interviewed at home. A total of 1,247 (99.5%) women with complete data were included. | Mean(SD): 43.2(+- 15.1) | | | | Overall: 9.1%
| | Taiwan | | | | Pre-menopausal: 6.8
| | | | | | Menopausal: 15.7%
Engstrom, 2003 ^125^ | A self-administered questionnaire. | Men | | | | Prevalence of Stress UI:
Level of evidence: II-2 | The questionnaire included items on three specific urinary symptoms: urgency, stress incontinence and post-micturition dribbling, and one question about health care-seeking behavior. | Age: 40–80yrs | | | | All ages: 2%
| A response rate of 86% was obtained in the questionnaire study. | Sweden | | | | 40–49yrs: 1%
| Definition: The Stress UI question asked the respondents whether they had experienced involuntary urinary loss in association with for example sneezing, lifting, or coughing. | | | | | 50–59yrs: 2%
| | | | | | 60–69yrs: 4%
| | | | | | 70–80yrs: 5%
Espino, 2003 ^126^ | Subject selection: A total of 1589 Mexican-American women aged 65 and older who were part of the Hispanic Established Population for the Epidemiologic Study of the Elderly. | Women 65 and older | | | | Prevalence
Cross-sectional | Definition: Stress incontinence symptoms were identified with the question: “During an episode of severe coughing, sneezing, vomiting, lifting, laughing, or straining, do you lose any urine?” | Mexican-American | | | | UI: 15%
Level of evidence: II-2 | Urge incontinence symptoms were determined by positive responses to the question, “Do you have a feeling of needing to urinate before you lose your urine?” | USA | | | | Stress: 10%
| | | | | | Urge: 33%
| | | | | | Mixed: 42%
Eva, 2003 ^127^ | Subject selection: 1000 women born in 1937 and 1000 women born in 1957 were randomly selected. | Women, aged 40 and 60yrs old. | | | | Prevalence
Level of evidence: II-2 | The 2000 women received a postal questionnaire concerning their medical and obstetric history, height and weight, exercise and professional activity, and urinary and fecal incontinence defined as flatus, liquid or solid stool. The incontinent women were asked how often leakages occurred. The urinary incontinent women were asked to complete a set of ten questions concerning voiding and leakage. | Sweden | | | | | Monthly | Weekly | Daily
| These questions were adapted from the detrusor instability score (DIS) developed by Kauppila. for detecting detrusor instability in incontinent women | | | | | 40-year-olds | 8% | 6% | 3%
| Response rate: 67 (%1336/2000) | | | | | 60-year-olds | 10% | 11% | 8%
| | | | | | UI weekly or more often:
| | | | | | Age | Prevalence,%
| | | | | | 19–44 | 9
| | | | | | 45–64 | 19
Goldberg, 2003 ^128^ | Subject selection: The study population included 769 mothers of multiples. | Age | | | | Prevalence
Level of evidence: II-2 | Response rate: 95.3% (733/769) attendees completed the survey. | Median: 37 years | | | | SUI: 45.5%
| | Range, 22–75 years | | | | UUI: 27.3%
| | Ethnicity 94% white, 2.3% black, 1% Hispanic, 0.6% Asian. | | | | Mixed: 22.9%
| | Parity
| | Mean: 3
| | Range: 2–12
| | USA
Grodstein, 2003 ^129^ | Subject selection: The Nurses' Health Study cohort was identified when 121,701 female, married registered nurses, 30 to 55 years of age who resided in 1 of 11 US states returned a mailed questionnaire in 1976.In 1996, information was requested regarding urinary function from study participants. Included were two questions to evaluate the frequency and extent of urine leakage and difficulty holding urine. | Age | | | | Prevalence
Prospective/Observational | Frequency and quantity of urine loss. Women were asked the question: “During the past 12 months. How often have you leaked urine or lost control of your urine?” with response categories of “never,” “less than once a month,” “once a month,” “2 to 3 times a month,” “about once a week,” and “almost every day.” Women who responded that they lost urine were then asked, “When you lose your urine, how much usually leaks?” with response categories of “a few drops,” “enough to wet your underwear,” “enough to wet your outer clothing,” and “enough to wet the floor.” | Mean: 60.4yrs | | | | (Reported leaking at least once per month)
Level of evidence: II-2 | | USA | | | | Overall: 17.7%
| | | | | | White: 17.9%
| | | | | | Black: 9.6%
| | | | | | Hispanic: 15.6%
| | | | | | Asian: 12.5%
| | | | | | 34.1% of the women reported leaking urine at least once per month during the previous 12 months. The prevalence of leaking urine appeared lower in the black, Hispanic, and Asian women compared with white women, although this was most marked for the black women (21.2%). Overall, 17.7% of the women said that they leaked at least once per week; again,
Hunskaar, 2004 ^20^ | Subject selection: Data collected using postal survey sent to 29,500 community dwelling women ≥18 years in 4 countries. | Women aged ≥18 years in France, Germany, Spain and the UK. | | | | Prevalence:
Prospective/observational | Definition: UI as any leakage or involuntary loss of urine. Stress UI as a leak or loss of urine caused by sneezing, coughing, exercising, lifting or physical activity. Urge UI as either as an urge to urinate but being unable to reach the toilet before leaking or having a strong sudden urge to go to the toilet to urinate with no advance warning. Mixed UI symptoms as at least 1 stress and 1 urge symptom. | | | | | Overall | SUI
II-2 | Response rate: 17,143/29,500 = 58.1% | | | | | Spain: 23%, | 39%
| | | | | | France: 44%, | 31%
| | | | | | Germany: 41% | 41UK:42%
| | | | | | UUI | MUI
| | | | | | Spain: 21% | 26%
| | | | | | France: 27% | 34%
| | | | | | Germany: % | 38%
| | | | | | UK:% | 34%
Hvidman, 2003 ^130^ | Subject selection: Cross-sectional survey in a random (age stratified) population sample of 3900 20- to 59-year-old women. The present study includes 376 women who had their last delivery during 1993-96. | 20- to 59-year-old women | | | | Prevalence
Cross-sectional | Definition: Included in the questionnaire was information on UI occurrence, irrespective of type, before and during separate parts of pregnancy, as well as occurrence and duration of PP UI [questions: ‘Did you have involuntary loss of urine in the time following the delivery?’ - ‘If so, how long a time (weeks) did it last after delivery?’]. The questionnaire applied was validated concerning the 6-month period prevalence of pregnancy and delivery independent of UI. | Denmark | | | | UI
II-2 | Response rate: 3900/6468 (60.3%) | | | | | Post partum: 23%
| | | | | | 6 months after delivery: 2.7%
Landi, 2003 ^131^ | Subject selection: Data was analyzed from a large collaborative observational study group, the Italian Silver Network Home Care project, that collected data on patients admitted to home care programs (n=5418). A total of 22 Home Health Agencies participated in this project evaluating the implementation of the Minimum Data Set for Home Care instrument. | Patients were Caucasian. | | | | Prevalence
Observational | | Women: 59% | | | | UI was recorded in 51% of patients, with a greater number of women than men showing this problem (52%vs 49%, respectively; P=0.01).
II-2 | | Mean age: 78.6 (+- 9.5 years) | | | | Three potentially reversible causes of UI showed the strongest association in both men and women:
| | Women had a mean age of 79.5 (+-9.5) years and were approximately 2 years older than men (77.4"9.4 years; P-0.001). | | | | These are: UTI (adjusted OR, 3.46; 95% CI, 2.65–4.51),
| | Marital status was substantially different between the two groups, with a higher prevalence of widowed among women compared to men. (58% vs. 24% respectively; P-0.001).Prevalence | | | | Use of physical restraints (adjusted OR, 3.20; 95% CI,2.19–4.68),
| | | | | | Environmental barriers (adjusted OR, 1.53; 95% CI, 1.15–2.02).
Maffezini, 2003 ^132^ | Subject selection: A total of 300 consecutive patients with histologically proven carcinoma of the prostate, staged as clinically organ-confined cT2 or less, underwent radical retropubic prostatectomy with the anatomic approach. | Men | | | | Prevalence
Observational | Definition: Patients were considered continent if they needed no protection to keep outer garments dry. | Age | | | | Twenty-six patients (8.8%) had a varying degree of stress incontinence requiring them to wear one to three pads per day.
II-2 | Patients were also considered continent if they occasionally leaked a few drops with abdominal straining.7 Patients who usually wore protection were considered as having stress incontinence. | Median:65.5 years | | | | 7 patients (2.3%) were incontinent, needing four or more pads per day.
| Patients who needed to use four or more pads during the day were considered incontinent. | Range:47 to 73 | | | | Of the 262 continent patients, 128 (48.2%) achieved complete urinary continence within the first day of catheter removal; the median time to recovery for the remaining 134 patients was 4 weeks (range 2 to 16).
| | Italy
Mawajdeh, 2003 ^133^ | Subject selection: The study was designed as a two-phase survey. The first phase consisted of a structured personal interview and the second phase was a follow-up physical examination. | Women | | | | Prevalence
Observational | 317 women were randomly selected and answered a questionnaire in the first phase of the study. | n=317 | | | | UI: 24%
II-2 | 301 (95%) of the 317 eligible women consented to the general examination. | Age: 18–49 yrs
| Two hundred sixty agreed to both the general physical and pelvic examination. The main outcome measures were selected reproductive and related nonreproductive morbidities. | Jordan
| Single women (n=7) and those suspected or confirmed pregnant (n=40) were not eligible for the pelvic exam due to cultural beliefs. 270 women were eligible for the pelvic exam of which 260 consented to the exam.
| Definition: UI
| Passing urine when laughing or coughing.
Miller, 2003 ^134^ | Subject selection: Five hundred participants were randomly selected from women in the young (aged 18–22 in 1996), mid-age (45–50), and older (70–75) cohorts of the Australian Longitudinal Study of Women's Health (ALSWH) who had reported leaking urine in the 1996 baseline survey. | 1500 women | | | | Prevalence
Observational (cohort) | Definition: Eligible respondents were defined as presently incontinent" if they had leaked even small amounts of urine in the previous month (or as “incontinent in the past” otherwise). Those with past incontinence were excluded from measurement of type and severity. | Comprise women from three age cohorts: young (then aged 18–22 years, but aged 21–26 at the time of the present study), mid-age (45–50, now 48–53 years), and older (70–75, now 73–79 years). | | | | MUI
II-2 | Response rates: 50, 83, and 80% in the young, mid-age, and older women, respectively. | Australia | | | | Young:86.6%
| The survey was completed by 50% of women sampled in the young cohort, 83% of the mid-age sample, and 80% of the sample of older women. Of those sampled in the young, mid-age, and older cohorts, 3.4, 0.4, and 1.2%, respectively, were ineligible for inclusion, either because they were deceased (n=2) or they reported “never having leaked even small amounts of urine.” Combining all age groups, 89% said they had leaked urine in the month before the survey. | | | | | Mid-age:92.3%
| | | | | | Older:91.1%
| | | | | | SUI:
| | | | | | Young:10.7%
| | | | | | Mid-age:6.4%
| | | | | | Older:2.0%
| | | | | | UUI:
| | | | | | Young:2.7%
| | | | | | Mid-age:1.3%
| | | | | | Older:6.1%
Miller, 2003 ^135^ | Subject selection: The sample for this study comprised 1,000 women who are current participants in the ALSWH, recruited in 1996 through random selection from the Medicare database. | The ALSWH sample included women in three age cohorts: young (then aged 18–22 years), mid-age (then aged 45–50, but aged 48–53 years at the time of this study), and older (70–75, now 73–79 years). | | | | Leaked urine
Observational | Five hundred participants were randomly selected from those in each of the mid-age and older cohorts who reported leaking urine “often” in the 1996 baseline survey of the ALSWH. | Australia | | | | Mid-age:94%
II-2 | Definition: A screening question asking whether the participant had ever leaked even small amounts of urine was included at the beginning of the survey to identify participants who may have responded inaccurately at baseline and were thus ineligible for inclusion in the study. | | | | | Older women:91%
| For the purposes of this study, respondents who had leaked even small amounts of urine in the month prior to completing the survey were considered presently “incontinent.” Those who indicated that they had not leaked in the last month were excluded from measurement of type and severity (because the scale for measuring type and severity asks about experience of symptoms “in the last month”), but they were asked to complete the remaining items about their previous experience of the problem and assistance sought. | | | | | Sought help or advice about their UI
| The survey was completed by 83% of the mid-age women and 80% of the older women sampled. Of those sampled in the mid-age and older cohorts, 0.4% and 1.2%, respectively, were ineligible for inclusion—either because they were deceased or they reported “never having leaked even small amounts of urine.” | | | | | Mid-age:72.2%
| | | | | | Older women:73.1%
Nuotio, 2003 ^136^ | Subject selection: The data come from the third wave of the Tampere longitudinal Study on Ageing (TamELSA) conducted in 1999 and included 429 survivors. | 171 men | | | | Prevalence
Cross-sectional | The response rate was 92.8%. | 227 women | | | | SUI
II-2 | Stress incontinence was defined as having urinary leakage during exertion, for example coughing or lifting. | Median age | | | | Men:2%
| Urge incontinence as having urinary leakage associated with a strong urge to urinate. | Men | | | | Women:23%
| Mixed incontinence was defined as reporting both stress and urge incontinence. | SUI: 80.5 | | | | UUI
| | UUI: 77 | | | | Men:17%
| | Mixed: 78 | | | | Women:6%
| | Women | | | | MUI
| | SUI: 76 | | | | Men:6%
| | UUI: 79 | | | | Women:30%
| | Mixed: 78
| | The median age for men without incontinence was 75 and for women 76 years.
| | Finland
Nuotio, 2003 ^137^ | Subject selection: The baseline data come from the second wave of the Tampere Longitudinal Study on Ageing (TamELSA), a population-based prospective study of living conditions, health, functioning, life styles, and use of services among older people in the city of Tampere, Finland. | Men and women | | | | Prevalence
Prospective, Observational | A total of 1036 persons aged 60–99 years were eligible to be interviewed face to face, using a structured questionnaire. | Aged 60–99 years | | | | UUI
II-2 | Response rate was 80%. | Finland | | | | Men:5.2%
| After exclusion of 53 subjects already living in institutions and 3 subjects without data on urinary symptoms, the baseline material consisted of 775 community-dwelling persons, of whom 366 were men and 409 were women. | | | | | Women: 14.7%
| Definition
| To define urge incontinence, the following question was asked: “Do you ever have trouble getting to the lavatory in time—yes or no?” In the case of a positive response, the following question was asked: “Do you have urinary leakage, either in the daytime or during the nights—never, rarely, frequently?” Urge incontinence was defined as having trouble getting to the lavatory in time with urinary leakage.
Parazzini, 2003 ^138^ | Subject selection: Cases,1,062 women with urinary incontinence or overactive bladder consecutively observed in first level gynecological centers. | Women | | | | Prevalence
Observational(Case-control) | Controls, 1,143 women observed in the same centre after the identification of the cases, without any symptoms related to UI or overactive bladder. | Age | | | | Overall
II-2 | Definition: UI as answering “yes” to the following question: “Have you had any involuntary urinary loss during the last month?” | Cases: 40 years or more (mean age 62.3 years, range 40–88) | | | | SUI: 2,58/1,062= 24.3%
| OAB without UI as answering “yes” to 1 or 2 of the following questions: “On average, do you urinate more than 8 times a day and/or >1 time/night?" or Have you any urgency symptoms?”, but answering no to the question: “Have you had any involuntary urinary loss during the last month?” | Controls: Mean age 58 years, range 40–86) | | | | UUI: 1,95/1,062= 18.4%
| | | | | | MUI: 4,86/1,062= 45.8%
| | | | | | OAB: 123/1,062= 11.6%
| | | | | | Age related
| | | | | | SUI | UUI
| | | | | | ≤52yrs:40.7% | 35.4%
| | | | | | 53–61:36.4% | 30.8%
| | | | | | ≥62: 22.9% | 33.9%
| | | | | | MUI | OAB
| | | | | | ≤52yrs:30.9% | 38.2%
| | | | | | 53–61:29.4% | 33.3%
| | | | | | ≥62: 39.7% | 28.5%
Peters, 2003 ^139^ | An age-sex-practice stratified random sample of 1420 patients registered with four general practices in South Bristol was selected. Forty-four patients were excluded because of illness, death or removals out of the area not yet amended on practice records.. | White: 99% | | | | Prevalence
Cross sectional | Response rates for the four practices varied at 56%, 62%, 68% and 71%, respectively. | A total of 915 responses were received (402 males and 513 females), of whom 496 (54%) were in the 65–74 years age range, and 419 (46%) were 75 years or older. | | | | UI: 39%
II-2 | The majority of respondents were married (54%) and one-third was widowed (33%). A minority were single, cohabiting or were divorced. Just over a third of people were living alone (38%) and nearly half had access to a car (48%). The majority of respondents were living in their own home (63%), with the next largest group (24%) living in local authority rented housing. | UK
Rortveit, 2003 ^140^ | Subject selection: The EPINCONT study, is part of the Nord-Trøndelag health Study 2 (HUNT 2), which was conducted in a county of Norway between 1995 and 1997. All women older than 20 years of age (a total of 47,313 women) received a mailed invitation to visit a screening station. The source population for the EPINCONT study consisted of the 34,755 community-dwelling women who attended the screening. Women were asked to complete a questionnaire at home, and 27,936 women (80 percent) answered questions related to incontinence. | Women | | | | Prevalence
Observational(Cohort) | Definition | Age | | | | Any incontinence: 20.7%
II-2 | If a woman answered yes to an entry question about any involuntary loss of urine, she was asked about the frequency of leakage (less than once a month, once or more per month, once or more per week, or every day, every night, or both), the amount of leakage each time (drops, small amounts, or large amounts), the circumstance of leakage (which could include coughing, sneezing, laughing, and lifting heavy items), whether leakage was accompanied by a sudden and strong urge to urinate, and to what extent she considered leakage a problem (no problem, a small nuisance, some bother, much bother, or a major problem). | Range: 20–64yrs | | | | Moderate /Severe incontinence: 8.7%
| | Norway | | | | SUI:12.2%
| | | | | | UUI:1.8%
| | | | | | MUI:5.9%
Dallosso, 2003 ^14^ | United Kingdom women age ≥40 living at home Part of the Leicestershire MRC Incontinence Study on prevalence and incidence including men and women. This study was women only. | Age: | | | | Prevalence of UI at baseline:
longitudinal, Prospective cohort | 19,239 eligible women; 65.3% returned N= 12,565. 6,424 responded to f/u questionnaire | 40–49 | 26% | | | Stress:17.3%
II - 2B | 7,046 women baseline with follow up collected from 6,426 1 yr later = began 10/98 with f/u in 10/99 | 50–59 | 27.4% | | | OAB: 16.3%
| Postal survey with usual definitions of SI. OAB defined by ICS and for this study as one or both of the sxs urge leakage and urgency. | 60–69 | 23.3% | | | Prevalence of OAB increased with age but no marked change in SI..3% reported SI at baseline.
| Subgroups of OAB and SI | 70–79 | 17.1%
| Excluded nursing home or residential pts and SI at baseline was excluded from analysis of onset of SI | >80 | 6.2%
| | BMI
| | Acceptable | 48.4%
| | Underwt | 7%
| | Overwt | 31.4%
| | Obese | 13.3%
| | Smoking
| | Never | 54.3
| | Exsmoker | 30.3
| | Current | 15.2
Stewart, 2003 ^141^ | Subject selection: National telephone survey using a clinically validated interview and a follow-up nested study comparing overactive bladder cases to sex-and age-matched controls. | Men and women | | | | Prevalence
Observational (Case-control) | A total of 17,231 households were contacted (includes 2,427 households where eligible members met criteria for region-sex-age-specific strata in which the sampling quota was filled) between November 2000 and January 2001. | >18years | | | | Overall
II-2 | Response rate: 68% (11,740/17,231) | USA | | | | OAB: 16.5%
| Eligible: 5,539 (47%) | | | | | OAB with UUI: 6.1%
| Definition: OAB without urge incontinence was defined by a feeling of urgency ≥4 times in the past 4 weeks and either >8 micturitions/day or the use ≥1 of the following coping strategies: restricting fluid intake, locating bathrooms in a new place, limiting travel, or defensive voiding. OAB with urge incontinence included the criteria for OAB without urge incontinence plus ≥3 episodes of urinary leakage in the past 4 weeks that was typical (i.e., frequency of episodes) and was not exclusively due to stress incontinence. | | | | | OAB without UUI: 10.4%
| | | | | | Women
| | | | | | OAB: 16.9%
| | | | | | OAB with UUI: 9.3%
| | | | | | OAB without UUI: 7.6%
| | | | | | Men
| | | | | | OAB: 16.0%
| | | | | | OAB with UUI: 2.6%
| | | | | | OAB without UUI: 13.4%
Talcott, 2003 ^142^ | Subject selection: Recruited patients who consulted physicians at participating sites for advice on primary therapy of pathologically-confirmed, untreated early (nonmetastatic) PC at the Massachusetts General Hospital, the Dana-Farber Cancer Institute, and affiliated clinics of the Joint Center for Radiation Therapy. | Men | | | | Prevalence
Prospective | Baseline questionnaires from 613 eligible patients were returned within 7 days of initiating treatment, a requirement to ensure that the reported baseline symptoms were free from the effects of therapy. 91 enrolled patients (14.9%) dropped out or died of unrelated causes (4 patients) before first follow-up questionnaire at 3 months after treatment, leaving 522 participating patients. Of the remaining patients, 27 patients (11%) had not yet been followed for 24 months, 66 patients (12.5%) dropped out before completing the 24-month questionnaires, and 429 patients (76.6%) continued through 24 months. | 46–82 years | | | | UI after radical prostatectomy
Observational (Cohort) | Definition: The urinary incontinence index assessed the degree of urinary control and the frequency and magnitude of leakage in men who had less than “complete control.” Five items assessed urinary obstruction and irritation: hesitancy, frequency of urination during the day, nocturia (urination at night), dysuria, and urgency. | Boston, MA | | | | Baseline: 4.9%
II-2 | | USA | | | | 3 months: 34.9%
| | | | | | 12 months: 23.9%
| | | | | | 24 months: 23.4%
Bogner, 2002 ^143^ | Epidemiologic Catchment Area (ECA) Program, a survey of psychiatric disorders in the general population between 1980 and 1984 at 1 of the 5 university-based sites in US (East Baltimore); data obtained from follow-up interviews which occurred in 1993 to 1996, with most in 1994 | Age range 50–96 years with mean age 67.2 (SD 10.8); Baltimore, MD, USA | | | | 20% (n=158) reported UI in past year
Cross-sectional | Randomly selected blocks based on expected number of households, with a random sample of households, and a randomly selected member within a household | 502 women (64%) | | | | - 127 women (25.3%); - 30 men (10.8%)
Adjusted for age, gender, ethnicity, chronic health conditions, education, ADL status | Over sampled older people by interviewing all persons in a household aged 65 and older | 279 men ((36%) | | | | 18% (n=29) reported condition-specific functional loss related to UI; 14 people reported 1 limitation, 7 reported 2 limitations, 5 reported 3 limitations, and 3 reported 4 limitations; not specified by gender
Level of evidence: II-3A | Structured interview in respondent's home by trained lay interviewers | 540 whites (69%) | | | | Adjusting for age, gender, ethnicity, and education, persons with UI were more likely to have psychological distress as measured by the General Health Questionnaire than person without UI (OR 1.56, 95% CI: 1.00–2.43)
| 781/820 persons aged 50 and over who had complete information on UI (95% analyzed) Excluded: unable to determine continence status in past year; missing GHQ scores | 207 African-Americans (27%) | | | | However, there was no significant difference between those with UI and those without in psychological distress after adjusting for IADL impairment and chronic medical conditions; Results were similar for men and women when considered separately
| UI Measurement: Have you ever had any difficulty in controlling your water, that is, losing your urine or having trouble getting to the bathroom in time during the past 12 months? | 26 American Indians, Hispanics, or Asians (4%) | | | | Among persons with UI, persons with persistently elevated General Health Questionnaire scores were more likely to report condition-specific functional impairment from UI (adjusted OR: 6.55, 95% CI: 1.94–22.12)
| Condition-Specific Functional Loss (4 questions): Because of UI, did they: avoid social gatherings, visiting friends, or going to church; avoid travel; not going shopping; and avoiding physical activities.
| Condition-specific functional loss due to UI was a positive response to any of the 4 questions
Buchsbaum., 2002 ^144^ | 149/190 nuns (78.4%) residing in two motherhouses | Women ages 39–91 years, with a mean age of 68, SD: 11.7; Rochester, NY, USA | | | | 74/149 (49.7%)
Retrospective cohort | Self-administered survey | 93.3% white (148/149) | | | | 63% slightly bothered
Adjusted for confounding factors | UI Measurement: Respondents asked if they had a current problem with urine loss | | | | | 25% moderately bothered
Level of evidence: II-2C | SUI and UUI determined from items on the IIQ | | | | | 4% greatly bothered
| | | | | | 52% used sanitary pads
| | | | | | 10.3% leaked once a day
| | | | | | 19.1% leaked several times a day
| | | | | | 29.7% SUI (n=22)
| | | | | | 24.3% UUI (n=18)
| | | | | | 35.1% MUI (n=26)
| | | | | | 10.8% UI unknown origin (n=8)
Finkelstein, 2002 ^145^ | Secondary analysis of responses to the second wave of the National Population Health Survey which surveyed Canadian households in 1996–97 | Men and women aged 30 years and older; Canada (10 provinces) | | | | Prevalence n reporting UI/ N of subjects and estimated rate per 100 using sampling weights
Cross-sectional | 27,263 households participated in 1994–95 (88.7% response rate); In 1996–97, 93.6% response rate | Race not specified | | | | Men
Adjusted by sampling weights, age, gender, income, and other confounding factors but not BMI which was not found to be associated with UI | Mailed survey | | | | | 30–39 years: | 35/7657, 0.2
Level of evidence: II-2C | UI Measurement: Do you have UI diagnosed by a health professional? | | | | | 40–49 years: | 40/6072, 0.4
| | | | | | 50–59 years: | 56/4438, 1.1
| | | | | | 60–69 years: | 121/,365, 2.7
| | | | | | 70–79 years: | 150/2614, 5.7
| | | | | | 80+ years: | 81/963, 6.4
| | | | | | Women:
| | | | | | 30–39 years: | 73/8218, 0.6
| | | | | | 40–49 years: | 116/6223, 1.6
| | | | | | 50–59 years: | 150/4948, 2.1
| | | | | | 60–69 years: | 190/4328, 3.9
| | | | | | 70–79 years: | 272/3892, 6.8
| | | | | | 80+ years: | 222/1901, 11.1
Landi, 2002 ^146^ | Population-based, longitudinal, multilinked database that comprises the Minimum Data Set for Home Care (MDS-HC) and their medications coded with the Anatomical Therapeutic Chemic classification system | Men and women ages 65 and over with mean age 77.1 (SD 11.9); Italy | | | | UI prevalence:
Cross-sectional | 4,583/4,717 patients admitted to home care programs in 22 home care agencies from 1997 to 2001 who participated in the National Silver Network Project (97.2% analyzed) | 58% female (n=2658) | | | | 33% of all patients
Adjusted by age, gender, ADL, cognitive performance, delirium, constipation, alcohol use, medications associated with increased UI risk) | Excluded: < 65 years, comatose, paraplegic, permanent indwelling catheter | 42% male (n=1925) | | | | 21% age 60–74
Level of evidence: II-2C | [underlined: UI Measurement]: Any involuntary loss of urine, regardless of amount, that occurred 2 or more times per week | 100% white | | | | 38% age 75 and over
| | | | | | 63% women (n=935)
Langa, 2002 ^82^ | Community-dwelling people ≥70 years, from the AHEAD cohort of the Health and Retirement Study by the University of Michigan. Response rate: 80.4% (n=7443) | Age: 70+ | | | | Prevalence:
Cross-sectional | Data source: In person or over the phone interviews. | Gender: Male and female | | | | Overall: 19.4%
Adjusted by: | Incontinence as, “Any loss of urine beyond your control in the last 12 months.” | Race: White, African-American, and Other | | | | By Gender:
Age, Race | | Ethnicity: Not reported | | | | Male: 13%
Gender, Net worth | | Residency: Michigan | | | | Female: 24%
Living situation | | | | | | By impact on life:
Chronic conditions | | | | | | Use of pads: 9.9%
Care giving received | | | | | | No use of pads: 9.5%
Level of evidence: III
Liu, 2002 ^147^ 2 | Randomly selected, Age-stratified population-based sample using the State Electoral Data Base of adults aged 70 and over in 1992; also included people living with the original selected persons | Men and women ages 70 years and over living in South Australia | | | | Unable to determine SUI and MUI prevalence because of problems with SUI definition
Prospective cohort | Health surveys at baseline, 12 and 24 months | Age stratified by 70–74, 75–79, 80–84, and 85 and over | | | | UUI in men across 3 waves:
Level of evidence: II-2C | 2272/4187 responded to initial mailed letter (53.2%) | Number of men and women not specified | | | | - Often: 6.6%, 8.5%, 6.2%; - Occasionally: 25.2%, 22.1%, 29.0%; - Never: 68.3%, 69.4%, 64.8%
| 2087/2272 (91.9%) completed all 3 surveys | Race not specified | | | | UUI in women across 3 waves:
| Unclear survey method at baseline and 24 months; 12 month survey conducted using a computer-assisted telephone interview | | | | | - Often: 10.2%, 10.6%, 8.9%; - Occasionally: 31.2%, 32.0%, 39.1%; - Never: 58.5%, 57.3%, 52.1%
| [underlined: UI Measurement]:: UUI: Do you have any difficulty holding your urine until you get to the toilet? (often, occasionally, never) | | | | | UUI in all and age-adjusted, respectively across 3 waves
| SUI: Do you accidentally pass urine? (often, occasionally, never) | | | | | - Often: 8.4%, 7.7%; - Occasionally: 28.2%, 27.5%; - Never: 63.5%, 64.8%
| MUI: Answer yes to both questions
| SUI definition according to currently accepted definitions is not SUI—interpreted as UI
Nuotio, 2002 ^148^ | Randomly selected, age and gender stratified population-based sample of home-dwelling and institutionalized adults aged 70 years and over from the third wave of the from the Tampere Longitudinal Study on Aging (TamELSA) in 1999 | 171 men and 227 women aged 70–98 years; Tampere, Finland | | | | Weighted UUI prevalence by age and gender:
Cross-sectional | 398/429 survivors from original study initiated in 1979 (92.8% response rate) | Race not specified | | | | Men
Adjusted by age and gender | Interview | | | | | - Age 70–79 years: 21.1%; - Age 80–98: 34.3%; - All ages: 28.9%
Level of Evidence: II-2C | [underlined: UI Measurement]: UUI: Urine leakage associated with a sudden urge to urinate, regardless of the frequency of urine loss (Does the urge to urinate ever become so strong that there is urinary leakage before you reach the lavatory? [no, yes, sometimes, frequently] | | | | | Women
| | | | | | - Age 70–79: 31.2%; - Age 80–98: 45.6%; - All ages: 41.8%
Peyrat, 2002 ^149^ | 1,700/2,800 (60.7% response rate) women employees in academic hospital assessed during annual exam with staff physician in 1998 | Women ages 20–62 (mean age 39.7 SD 8.0); France | | | | UI: 27.5% (n=467; CI: 25.4–29.7) reported UI
Cohort | Self-administered questionnaire | Race not specified | | | | SUI: 12.4%, n=210, CI: 10.8–14.0)
Adjusted?? | [underlined: UI Measurement]: Do you currently have some involuntary leakage of urine? | | | | | UUI: 1.6% (n=28, CI: 1.1–2.4)
Level of evidence: II-2C | | | | | | MUI: 13.5% (n=229, CI: 11.9–15.2)
| | | | | | Prevalence by Age and UI Type
| | | | | | - Any UI; - < 25: 2/32 (6%); - 25–39: 150/823 (18.2%); - 40–55: 266/699 (38.0%); - > 55: 16/34 (47%); - SUI; - < 25: 1/32 (3%); - 25–39: 68/823 (8.3%); - 40–55: 121/699 (17.3%); - > 55 8/34 (24%); - UUI; - < 25: 0; - 25–39: 12/823 (1.5%); - 40–55: 12/699: (1.7%); - > 55: 0; - MUI; - <25: 1 (3%); - 25–39: 70 (8.5%); - 40–55: 133 (19.0%); - > 55: 8 (24%)
| | | | | | Prevalence Below and Above Age 40 by UI Type
| | | | | | - ≤40: Any UI: 152/855 (17.8%); SUI: 69 (8.1%); UUI: 12 (1.4%); MUI: 71 (8.3%); - > 40: Any UI: 282/733 (38.5%); SUI: 210 (12.4%): UUI: 28(1.6%); MUI: 229 (13.5%)
| | | | | | By Frequency:
| | | | | | - Occasional: Any UI: 429 (91.9%); SUI: 209 (99.5%); UUI: 24 (85.7%) MUI: 196 (85.6%); - Permanent (e.g., frequent: defined as 2 episodes of urethral loss every day): Any UI: 38 (8.1%); SUI: 1 (0.5%); UUI: 4(14.3%); MUI: 33 (14.4%)
Pregazzi, 2002 ^150^ | Consecutive sample of 537 women who had a vaginal delivery between April 1999 and February 2000 | 537 women aged 19–44 years; Italy | | | | SUI:
Case control | In-person interview and underwent a urogynecologic examination 3 months after vaginal delivery | Race not specified | | | | - Total: 63 (11.7%); - Primparae: 31 (8.2%); - Multiparae: 32 (20.3%); - P =.0001
Adjusted for maternal age, parity, induced labor with prostaglandins, type of vaginal delivery, dysuria, urgency, frequency, pre-pregnancy maternal weight, pregnancy weight gain | [underlined: UI Measurement]: SUI: loss of urine on physical effort UUI: loss of urine associated with a strong desire to void | | | | | UUI:
Level of evidence: II-3 | | | | | | - Total: 41 (7.6%); - Primparae: 21 (5.5%); - Multiparae: 20 (12.7%); - P =.004
Sampselle, 2002 ^151^ | 3302 participants ages 42–52 from the Study of Women's Health Across the Nation (SWAN) which studied the natural history of the menopausal transition | Women with a mean age of 46.4 (SD 2.7) from 7 USA cities (Boston, Chicago, Detroit, Los Angeles, Newark, Pittsburgh, Oakland, CA) | | | | Any UI:
Prospective cohort | Included: Intact uterus with one ovary, pre-or early menopause, not currently using exogeous hormone preparations affecting ovarian function, self-identification with one of each site's designated race/ethnic groups, use of English, Spanish, Japanese, Cantonese, and ability to give verbal consent | 47.0% white (n=1530) | | | | - 56.9% of total group; - 66.0% white; - 49.5% black; - 50.2% Chinese; - 41.4% Hispanic; - 52.9% Japanese
Adjusted for confounding factors, site, age, and ethnicity | Random sampling from 7 cities using census lists, commercial electric utility household lists, Kaiser Permanente membership lists, or random digit dialing depending on site | 28.1% Black (n-915) | | | | Mild UI
Level of evidence: II-2A | Self-administered questionnaire | 7.6% Chinese (n=249) | | | | - 32.1% total group; - 36.9% white; - 26.0% black; - 34.1% Chinese; - 22.3% Hispanic; - 34.4% Japanese
| [underlined: UI Measurement]: In the past year, have you ever leaked even a very small amount of urine involuntarily? | 8.7% Hispanic (n=284) | | | | Moderate UI
| UI severity derived by multiplying frequency of urine loss score by volume score; slight UI= score of 1 or 2; moderate UI: 3–4; severe UI: >4 | 8.6% Japanese (n=280) | | | | - 14.6% total; - 16.8% white; - 14.1% black; - 11.6% Chinese; - 9.6% Hispanic; - 11.8% Japanese
| | | | | | Severe UI
| | | | | | - 9.9% total; - 12.1% white; - 8.8% black; - 4.4% Chinese; - 9.2% Hispanic; - 6.4% Japanese
| | | | | | 25% wear protection or change undergarments on several days per week
| | | | | | UI severity strongly associated with bother (mild as reference):
| | | | | | - Moderate UI: OR 3.61, 2.84–4.57); - Severe UI: OR 16.93, 11.60–24.70
| | | | | | Ethnicity and bother (white women as reference)
| | | | | | - Black: OR 1.26, 0.95–1.67; - Chinese: OR .69, .39–1.22; - Hispanic: OR 5.70, 2.70–12.03; - Japanese: OR 1.55, .92–2.61
Sebesta, 2002 ^152^ | TRICARE/CHAMPUS claims database searched to identify 1,000 patients who underwent radical prostatectomy for localized prostate cancer between 1995 and 1996; Prostatectomy had to be within 18 months of study initiation; patients were < 65 years at time of surgery and had at least 18 months of follow-up | Men < 65 years of age at time of surgery; USA in multiple states | | | | UI in past week:
Retrospective Cohort | Out of 1,000 patients, 136 surveys were undeliverable because of the patient's death or inaccurate address | Race not specified | | | | - None: 295 (43.7%); - Several per week: 73 (10.8%); - < 1/day: 131 (19.4%); - 1/day: 113 (16.8%); - > 1/day: 62 (9.2%); - 56.3% reported at least one UI episode in past week—this differs from above which relates to how the questions were worded
No adjustment | 674/864 (78% response rate) | | | | | With physical exertion: 343 (50.8%)
Level of evidence: II-2C | Mailed questionnaire | | | | | UUI only: 35 (5.2%)
| [underlined: UI Measurement]: Questioned only about postoperative continence by eliciting information regarding the frequency, time, and type of leakage, and use of protective devices and incontinence treatment | | | | | Sudden urge/no time: 117 (17.4%)
| | | | | | While in bed/running to bathroom: 51 (7.6%)
| | | | | | 31.7% use pads or other protective devices
| | | | | | - 8% of these used 2 or more pads/day
| | | | | | 12% reported UI was a problem
Sze, 2002 ^153^ | Women seeking gynecologic care between May 2000 and June 2001 at the Brody Medical School Clinic and Office of East Caroline University Women's Physicians | Women ranging in age from 15–91; North Carolina, USA | | | | UI prevalence by race (P < .001):
Cross-sectional | Excluded: urogynecologic and obstetric clinic patients | 34% Black (n=799) | | | | - 41% White; - 31% Black; - 30% Hispanic
Adjusted by age and parity | 2370 women (response rate not reported) | 39% white (n=932) | | | | SUI: (P <.001)
Level of evidence: II-2C | Self-administered questionnaire | 639 Hispanic (n=639) | | | | - 39% white; - 27% Black; - 24% Hispanic
| UI Measurement: Do you lose urine when you cough, sneeze, lift, jump, or get up from a bed or chair? | | | | | UUI: (P = NS)
| Do you wear a pad or protective undergarment because you lose urine when you cough, sneeze, lift, jump, or get up from a bed or chair? | | | | | - 19% white; - 16% Black; - 16% Hispanic
| Do you lose urine less than 5 minutes after you feel the urge to urinate more than once per week?
Thompson, 2002 ^154^ | All women living in the Australian Capital Territory who gave birth to a live baby between March to Oct 1997 in one of the two public hospitals and completed 4 questionnaires; study was part of a project to determine risk factors for postnatal depression | Women aged 16 years and over | | | | Point prevalence of UI by delivery method at 8, 16, and 24 weeks postpartum
Prospective cohort with 24 week postpartum follow-up | Measurement on 4^th^ postpartum day, at 8, 16, and 24 weeks postpartum | | | | | - Unassisted vaginal delivery; - 0–8 weeks: 178 (21%); - 9–16 weeks: 109 (13%); - 17–24 weeks: 14 (3%)
Adjusted for delivery method and parity | 1295 women (70%) agree to participate, and of these 1193 (92%) retained in the cohort through 24 weeks postpartum
Level of evidence: II-2A | Mailed questionnaire
| UI Measurement: Thinking about your health and how you have been feeling over the past 8 weeks, have any of the following been a problem for you? UI (e.g., hard to hold urine when coughing, sneezing, or exercising)
Van der Vaart, 2002 ^155^ 2 | Random population-based sample of women ages 35–70 years obtained from the population registration office of a suburban area in Netherlands | Women ages 35–70 years; Central Netherlands | | | | Overall UI: (P <.01)
Cross-sectional cohort study | 1626/2322 women (70% response rate) | Race not specified | | | | - Non-hysterectomy: 902/1417, 49.3%; - Hysterectomy: 133/209, 64.0%
Adjusted by age, educational level, parity, and hysterectomy status | Mailed questionnaire | | | | | SUI: (P=NS)
Level of evidence: II-2C | [underlined: UI Measurement]: Urogenital distress Inventory | | | | | - Non-hysterectomy: 716/1417, 50.5%; - Hysterectomy: 118/209, 57.0%; - Bothersome SUI: 120, 8.5%, P=NS
| SUI: Do you experience urine leakage related to physical activity, coughing, or sneezing? | | | | | UUI: (P <.0001)
| UUI: Do you experience urine leakage related to a feeling of urgency? | | | | | - Non-hysterectomy: 320/1417, 22.6%; - Hysterectomy: 80/209, 38.3%; - Bothersome UUI: 21, 9.7%, P <.0001
| Overall UI: having SUI or UUI
Van der Vaart, 2002 ^156^ ? | Random, population-based sample of women aged 20–45 years obtained from the population registration office of a suburban area in 1999 | Women aged 20–45; | | | | 365 (39.1%) SUI
Cross-sectional cohort | 1029/1393 (73.9% response rate) | Mean age 34.2, SD 3.2 years; Central Netherlands | | | | 143 (15.3%) UUI
Not adjusted | Mailed questionnaire | Race not specified | | | | Prevalence without (n=1417) and with hysterectomy (n=209), respectively, P-value:
Level of evidence: II-2 | [underlined: UI Measurement]: Urogenital Distress Inventory: | | | | | - Overall UI: 902 (49.3%) vs. 133 (64.0%) P < .01; - SUI: 716 (50.5%) vs. 118 (57.0), NS; - Bothersome SUI: 120 (8.5%) vs. 23 (11.1%), NS; - UUI: 320 (212.6%) vs. 80 (38.3%), P <.0001; - Bothersome UUI: 44 (3.1%) vs. 21 (9.7%), P <.0001
| SUI: do you experience urine leakage related to physical activity, coughing, or sneezing?
| UUI: do you experience urine leakage related to the feeling of urgency?
Van Oyen, 2002 ^157^ | Multistage sampling using the National population Register | 3,462 men and 3,804 women ages 15 and over; Belgium | | | | Weighted prevalence to Belgium population of age 15 years and over:
Retrospective cohort | 7,706 participants who were part of the 1997 Belgian Health Interview Survey ≥15 years | Race not specified | | | | - 1.4% men (n=92); - 4.6% women (n=234)
Prevalence estimates weighted by age and gender distribution of Belgian population age 15 and over | Excluded: Proxy reports | | | | | UI in men by age and frequency:
| Participation was 60% at household level; once a household participated, the refusal rate was 2.5% | | | | | - 15–24: .1% (n=443); <1/mo: 100%; - 25–34: 0 (n=680); - 35–44: .6% (n=705); 100% at least 1 x/mo; - 45–54: 0.9% (n=599); 33.3% at least 1x/mo, 66.7% at least 1x/wk; - 55–64: 2.7% (n=428), 15.4% < 1x/mo, 21.2% at least 1x/mo, 63.5% at least 1x/wk; - 65–74: 5.2% (n=384); 6.8% < 1x/mo, 18.8% at least 1x/mo; 73.7% at least 1x/wk; - 75+: 13.3% (n=223), 6.8% < 1x/mo, 18.8% at least 1x/mo, 73.7% at least 1x/wk; - TOTAL: 1.4% (n=3462), 14.3% < 1x/mo, 28.6% at least 1x/mo, 57.1% at least 1x/wk
| 7,266 eligible subjects all participated | | | | | UI in women by age and frequency:
| Interview at home using WHO-instrument | | | | | - 15–24: 0.2 (n=481), 100% at least 1x/wk; - 25–34: 1.8% (n=753), 22.2% < 1x/mo, 16.7% at least 1x/mo, 61.1% at least 1 x/wk; - 35–44: 2.3% (n=709), 8.7% < 1x/mo, 26.1% at least 1x/mo, 65.2% at least 1x/wk; - 45–54: 3.8% (N=557), 21.1% at least 1x/mo, 21.1% at least 1x/mo, 57.9% at least 1x/wk; - 55–64: 8.6% (n=461), 31.4% < 1x/mo, 12.8% at least 1x/mo, 55.8% at least 1x/wk; - 65–74: 11.7% (n=509); 22.2% < 1x/mo, 26.5% at least 1x/mo; 50.4% at least 1x/wk; - 75+: 21.0% (n=334), 4.3% < 1x/mo, 58.6% at least 1x/mo, 37.6% at least 1x/wk; - TOTAL: 4.6% (n=3904) 17.4.3% < 1x/mo, 30.4% at least 1x/mo, 52.2% at least 1x/wk
| [underlined: UI measurement]: Do you sometimes lose control of your bladder?
| If yes, how often do you lose control of your bladder? (at least once a week, less than once a week but at least once a month, less than once a month
Maggi, 2001 ^158^ | Subjects were randomly selected from non-institutionalized individuals aged 65 and older. The names and addresses were obtained by resident lists maintained by the municipalities of Northeastern Italy. | Age: 65 and older | | | | Prevalence:
Cross-sectional | Response rate: 89% (n=2,402) | Mean age (Men): 75.2 | | | | Overall Male=11.2% -Female=21.6%
Adjusted by: | Data source: At home interviews | Mean age (Women): 76.9 | | | | By Age Group:
Age | Incontinence was defined by the interviewer asking, “If they had UI problems, and how often they occurred.” | Gender: Male and female | | | | Male:
Gender | | Male: 36% | | | | Age Group | Prevalence %
Marital status | | Female: 64% | | | | 65–69 | 4.6
Education | | Race: Not reported | | | | 70–74 | 12.6
Mental health | | Ethnicity: Not reported | | | | 75–79 | 12.3
Physical health | | Residency: Veneto | | | | 80–84 | 22.2
BMI | | Region, Italy | | | | 85+ | 23.6
Self-rated health | | | | | | Total | 11.5
Sleep medications | | | | | | Female:
Alcohol use | | | | | | Age Group | Prevalence %
Cigarette smoking | | | | | | 65–69 | 16.4
Diarrhea | | | | | | 70–74 | 17.8
Co-morbidity | | | | | | 75–79 | 24.8
ADL disability | | | | | | 80–84 | 23.9
Mobility disability | | | | | | 85+ | 34.7
COPD | | | | | | Total | 21.6
Parkinsonism
Hip fracture
Night awakening
Level of evidence: III
Maral, 2001 ^159^ | Subjects were selected from people at an education and research health district in Turkey >15.years | Age: ≥15 years | | | | Prevalence (Stress):
Cross-sectional | Response rate: 90.8% (n=2261) | Gender: Male and Female | | | | Overall: 11.1%
Adjusted by: | Data source: Self-reported interviews. | Race: Not reported | | | | Male: 1.0%
Age | Incontinence was defined as, “Urinary leakage while coughing, straining, sneezing, or lifting heavy objects.” (Stress) | Ethnicity: Not reported | | | | Female: 20.8%
Gender | | Residency: Turkey | | | | By Age:
Parity | | | | | | 15–24:
Systemic disease | | | | | | Male: 0%
Previous surgery | | | | | | Female: 8.3%
Level of evidence: III | | | | | | 25–34:
| | | | | | Male: 0%
| | | | | | Female: 20.4%
| | | | | | 35–44:
| | | | | | Male: 0.9%
| | | | | | Female: 24.9%
| | | | | | 45–54:
| | | | | | Male: 1.2%
| | | | | | Female: 29.6%
| | | | | | 55–64:
| | | | | | Male: 3.8%
| | | | | | Female: 28.3%
| | | | | | 65 and older:
| | | | | | Male: 4.9%
| | | | | | Female: 33.7%
MacLennan, 2000 ^84^ | Subjects were randomly selected from households as part of the 1998 South Australian Health Omnibus Survey. The person with most recent birthday in selected household was interviewed. | Age: 15–97 years old | | | | Male:
Cross-sectional | Response rate: 73.3% (n=3,010) | Gender: Male and female | | | | UI Type | Prevalence %
Adjusted by: Age, Sex, Income, Country of birth, Method of delivery, BMI, Coughing, Osteoporosis, Arthritis Pelvic floor surgery | Data source: At home interviews by trained female interviewers. | Male: 48.7% | | | | Stress | 1.5
Level of evidence: III | Incontinence as, “lost urine when coughing, laughing, or sneezing or accidentally wetting before reaching the toilet.” | Female: 51.3% | | | | Urge | 1.9
| | Race: Not reported | | | | Mixed | 1
| | Ethnicity: Not reported | | | | Total | 4.4
| | Residency: Australia | | | | Female:
| | | | | | UI Type | Prevalence %
| | | | | | Stress | 20.8
| | | | | | Urge | 2.9
| | | | | | Mixed | 11.6
| | | | | | Total | 35.3
Muscatello, 2001 ^160^ | Subjects were selected from randomly selected households as part of the 1997 NSW Health Survey of Australia. One person was randomly selected from each household. Selection was from central Sydney. | Age: 41 and over | | | | Male:
Cross-sectional | Response rate: 68% | 41–49: 35% | | | | Type/Age | Prevalence %
Adjusted by: | Data source: Computer assisted telephone interviews relying on self-reported data. | 50–59: 26% | | | | Urge
Age | Incontinence was defined as, “Sudden and unexpected need to urinate (Urge),” and “Leaking urine during physical activity, coughing, or sneezing (Stress).” The symptoms needed to occur within the past month. | 60–69: 17% | | | | 41–49 | 7
Sex | | 70+: 22% | | | | 50–59 | 2
Country of birth | | Gender: Male and female | | | | 60–69 | 18
Language | | Male: 47% | | | | 70+ | 17
Marital status | | Female: 53% | | | | Total | 9
Education | | Race: Not reported | | | | Stress
Insurance access | | Ethnicity: Not reported | | | | 41–49 | 7
Self-reported health | | Residency: Sydney, Australia | | | | 50–59 | 2
Mental health status | | | | | | 60–69 | 25
Smoking | | | | | | 70+ | 11
Alcohol consumption | | | | | | Total | 9
Physical activity | | | | | | Female:
Bodyweight | | | | | | Type/Age | Prevalence %
Diabetes | | | | | | Urge
Hysterectomy status | | | | | | 41–49 | 18
Level of evidence: III | | | | | | 50–59 | 33
| | | | | | 60–69 | 38
| | | | | | 70+ | 32
| | | | | | Total | 29
| | | | | | Stress
| | | | | | 41–49 | 29
| | | | | | 50–59 | 42
| | | | | | 60–69 | 46
| | | | | | 70+ | 27
| | | | | | Total | 35
Patel, 2001 ^161^ | 324 incident cases of stroke with incontinence 1 week post-stroke identified from South London stroke register from January 1, 1995, to December 31, 1998. | Men and Women | | | | Prevalence of UI
Prospective | Definition: indwelling catheter within 48hrs of assessment or loss of bladder control. | UK | | | | 39%
Observational
II-2
Schmidbauer, 2001 ^62^ | Subjects were selected from free of charge health examinations sponsored by the city of Vienna. | Age: 20 years and older | | | | Prevalence:
Cross-sectional | Response rate: Not reported (n=2,498) | Male mean: 48.6 (SD: 13.0) | | | | Overall:
Adjusted by: Age, Gender, BMI, Education, Weight, Alcohol, Smoking, Urgency, Frequency, Nocturia, Intermittency, Reduced Stream, Childbirth, Incontinence Surgery, Hysterectomy, Vaginal surgery, Prostatectomy, Blood pressure, Serum triglyceride, Fasting glucose | Data source: Self-reported questionnaire | Female mean: 49.7 (SD: 13.6) | | | | Male: 5%
Level of evidence: III | Incontinence was defined as, “Any involuntary loss of urine within the past four weeks.” | Gender: Male and Female | | | | Female: 26.3%
| | Male: 49.5%
| | Female: 50.5%
| | Race: Not reported
| | Ethnicity: Not reported
| | Residency: Vienna, Austria
Stoddart, 2001 ^162^ | Subjects were randomly selected from a stratified sample of 2000 community living elderly from 11 general practices in a British city. | Age: 65 years and older | | | | Male
Cross-sectional | Response rate: 79% (n=1,521) | Gender: Male and female | | | | Age group | Prevalence %
Adjusted by: | Data source: Self-reported mailed questionnaire | Male: 51.3% | | | | 65–69 | 12
Age | Incontinence was defined as subjects, “Reporting that in the last month they leaked urine or indicated how much leakage occurred, that they protected themselves against leakage, or that leakage happened at a defined time.” | Female: 48.7% | | | | 70–74 | 21
Sex | | Race: Not reported | | | | 75–79 | 22
Level of evidence: III | | Ethnicity: Not reported | | | | 80+ | 34
| | Residency: Great Britain | | | | Total | 23
| | | | | | Severity
| | | | | | Underwear damp | 17.4
| | | | | | Underwear wet | 2.2
| | | | | | Wet outer clothes/floor | 1
| | | | | | Whether UI a problem
| | | | | | Y | 11.4
| | | | | | By Type
| | | | | | Stress | 3.3
| | | | | | Urge | 10.1
| | | | | | Female
| | | | | | Age group | Prevalence %
| | | | | | 65–69 | 29
| | | | | | 70–74 | 22
| | | | | | 75–79 | 31
| | | | | | 80+ | 42
| | | | | | Total | 31
| | | | | | Severity
| | | | | | Underwear damp | 20.3
| | | | | | Underwear wet | 4.5
| | | | | | Wet outer clothes/floor | 2.8
| | | | | | Whether UI a problem
| | | | | | Y | 16
| | | | | | By Type
| | | | | | Stress | 17.7
| | | | | | Urge | 16.9
Aggazzotti, 2000 ^163^ | Subjects were selected from institutionalized people living in the district of Modena, Italy. Figures provided by the Social and Health Care Authority were used to identify and survey 14 institutions. | Age: Mean: 82 (SD: 10; Range: 33–102) | | | | Prevalence:
Cross-sectional | Response rate: 89.8% (n=839) | Gender: Male and female | | | | Overall: 54,500 / 100,000 (54.5%)
Adjusted by: | Data source: Questionnaire prepared specifically for the study. Data was collected from both clinical records and from physicians and nurses of the residents. | Race: Not reported | | | | By Gender:
Age | Urinary incontinence was defined as, “the involuntary loss of urine occurring at least twice a week.” | Ethnicity: Not reported | | | | Male: 39,200 / 100,000 (39.2%)
Gender | | Residency: Institutions in Modena, Italy | | | | Female: 59,800 / 100,000 (59.8%)
Mental orientation
Mobility
Urinary tract infection
Constipation
Fecal incontinence
Neurologic disease
Psychiatric disease
Hypertension
Diabetes
Cardiovascular disease
Bone fracture
Level of evidence: III
Alling-Moller, 2000 ^164^ | Subjects were selected randomly from women in the Danish Civil Registration System, which contains everyone living in Denmark. The subjects were selected from the urban county Copenhagen and the rural county Storstroms. All subjects were between 40 and 60 years of age. | Age: 40–60 years of age | | | | Prevalence:
Case-control | Response rate: | 40–44: 22% (n=228) | | | | Overall: 46,300 / 100,000 (46.3%)
Adjusted by: | Cases: 97% (n=487) | 45–49: 20% (n=207) | | | | By Type (of those who are incontinent):
Age | Controls: 76% (n=564) | 50–54: 21% (n=216) | | | | Stress Incontinence: 64,300 / 100,000 (64.3%)
Physical activity | Data source: Validated, self-reported questionnaire | 55–59: 20% (n=211) | | | | Urge incontinence: 35,500 / 100,000 (35.5%)
BMI | Definition of incontinence: “The definitions of stress and urge incontinence were those defined by the International Continence Society.” | 60: 18% (n=189) | | | | Continuous incontinence: 14,100 / 100,000 (14.1%)
Abortion | | Gender: Female | | | | Nightly incontinence: 4,000 / 100,000 (4%)
Parity | | Race: Not reported
Fetal weight | | Ethnicity: Not reported
Episiotomy | | Residency: Counties of Copenhagen and Storstroms, Denmark
Lesion of anal sphincter
Repair of uterine prolapse
Cystocele repair
Hysterectomy
Constipation
Straining at stool
Hormonal inactivity
Use of diuretics
Cystitis treated w/antibiotics
Medication for noninfectious urinary symptoms
County
Level of evidence: II-3
Bortolotti, 2000 ^165^ | Subjects were selected from randomly identified individuals from a network of general practitioners in Italy from 3/97–10/97. Computer generated random number lists were used. | Age: | | | | Males:
Cross-sectional | Response rate: “Practically 100%” (n=5,488) | ≥40 (Female) | | | | Age category | Prevalence %
Adjusted by: Age, Sex, BMI, Education, Smoking, Alcohol and Coffee consumption, Abdominal or Pelvic surgery, BPCO, Diabetes, Urinary infections, Perineal trauma, Enuresis, Neurological disease, Parity | Data source: At home interviews | ≥50 (Male) | | | | 51–60 | 2
Level of evidence: III | Incontinence was defined as, “Loss of urine in the last year.” | Gender: | | | | 61–70 | 2.6
| | Male: 49.6% | | | | 70+ | 6.6
| | Female: 50.4% | | | | Total | 3.4
| | Race: Not reported | | | | Females:
| | Ethnicity: Not reported | | | | Age category | Prevalence %
| | Residency: Italy | | | | 40–50 | 7.2
| | | | | | 51–60 | 11.8
| | | | | | 61–70 | 9.5
| | | | | | 70+ | 15.9
| | | | | | Total | 11.4
Hannestad, 2000 ^166^ | Subjects were selected from all females in a particular county. The study was a part of the HUNT 2 survey. | Age: ≥20 years | | | | Age group | Prevalence % | Stress | Urge | Mixed
Cross-sectional | Response rate: 80% (n=27,936) | Gender: Female | | | | 20–24 | 10 | 48 | 13 | 33
Adjusted by: | Data source: Self-reported questionnaire | Race: Not reported | | | | 25–29 | 14 | 54 | 13 | 28
Age | Incontinence defined as, “Involuntary loss of urine.” | Ethnicity: Not reported | | | | 30–34 | 18 | 59 | 10 | 27
Level of evidence: III | | Residency: Norway | | | | 35–39 | 21 | 60 | 7 | 29
| | | | | | 40–44 | 24 | 60 | 8 | 29
| | | | | | 45–49 | 28 | 65 | 7 | 27
| | | | | | 50–54 | 30 | 55 | 7 | 36
| | | | | | 55–59 | 28 | 52 | 9 | 37
| | | | | | 60–64 | 26 | 42 | 10 | 46
| | | | | | 65–69 | 27 | 38 | 16 | 44
| | | | | | 70–74 | 30 | 33 | 16 | 48
| | | | | | 75–79 | 34 | 34 | 19 | 44
| | | | | | 80–84 | 35 | 32 | 21 | 40
| | | | | | 85–89 | 35 | 28 | 23 | 40
| | | | | | 90+ | 40 | 28 | 12 | 48
| | | | | | Total | 25 | 50 | 11 | 36
| | | | | | By Severity
| | | | | | Age group | Unknown | Slight | Moderate | Severe
| | | | | | 20–24 | 0.3 | 6.3 | 2.5 | 1.3
| | | | | | 25–29 | 0.6 | 8 | 4.5 | 1.2
| | | | | | 30–34 | 1 | 10.7 | 4.9 | 1.6
| | | | | | 35–39 | 1.1 | 11.5 | 6 | 2.6
| | | | | | 40–44 | 1.6 | 11.6 | 7.5 | 3.3
| | | | | | 45–49 | 2.4 | 13.7 | 8.3 | 4.1
| | | | | | 50–54 | 3 | 12.3 | 8.8 | 6.1
| | | | | | 55–59 | 3.1 | 9.3 | 8.4 | 6.8
| | | | | | 60–64 | 3.6 | 7.8 | 7.6 | 7.2
| | | | | | 65–69 | 4.8 | 5.6 | 8.3 | 8.7
| | | | | | 70–74 | 4 | 5.7 | 8.1 | 12.1
| | | | | | 75–79 | 4.2 | 7 | 8.1 | 14.6
| | | | | | 80–84 | 5.2 | 5.9 | 8.1 | 16.1
| | | | | | 85+ | 5.7 | 2.6 | 8.2 | 19.3
| | | | | | Impact on life | Prevalence of impact %
| | | | | | No problem | 5
| | | | | | Small nuisance | 11.3
| | | | | | Some bother | 5.7
| | | | | | Much bothered | 1.4
| | | | | | Great problem | 1
Gavira-Iglesias, 2000 ^167^ | Subjects were randomly selected from a representative sample of people ≥65years in the Basic Health Zone of Cabra in Spain. | Age: Mean: 77.7 (SD: 8.1) | | | | Gender | Prevalence %
Cross-sectional | Response rate: 95% (n=827) | Gender: Male and Female | | | | Male | 28.7
Adjusted by: | Data source: Home health interview conducted by the investigators and relying on self-reported symptoms. | Male: 41% (n=341) | | | | Female | 41.6
Age | Incontinence was defined as a positive response to the question, “Do you ever have involuntary or unexpected leakages of urine without being able to control them?” Or a positive response to the question, “Do you ever wet or dampen your underwear, clothes, or bedclothes against your will?” In addition, anyone using a urinary catheter or absorbent pads was also considered incontinent. | Female: 59% (n=486) | | | | Male:
Marital status | | Race: Not reported | | | | Frequency | Prevalence %
Educational level | | Ethnicity: Not reported | | | | <Monthly | 0.2
Living status | | Residency: Municipal districts or Cabra, Dona Mencia, and Nueva Carteya in Spain. | | | | Monthly | 7.8
Urethral catheter use | | | | | | Weekly | 12.4
Level of functioning | | | | | | Daily | 5.8
Level of evidence: III | | | | | | Unknown | 2.5
| | | | | | Severity | Prevalence %
| | | | | | Drops or small amount | 20.8
| | | | | | Large amount | 7.9
| | | | | | Female:
| | | | | | Frequency | Prevalence %
| | | | | | <Monthly | 0.9
| | | | | | Monthly | 7.5
| | | | | | Weekly | 20.1
| | | | | | Daily | 8.9
| | | | | | Unknown | 4.2
| | | | | | Severity | Prevalence %
| | | | | | Drops or small amount | 28.8
| | | | | | Large amount | 12.8
Roe, 2000 ^168^ | Subjects were selected from random samples of the adult populations generated from patient registers of the Family Health Services Authorities in the UK. | Age: 18–98 | | | | Age group | Prevalence %
Cross-sectional | Response rate: 53% (n=6,139) | Gender: Male and female | | | | 18–29 | 3.1
Adjusted by: | Data source: Self-reported mailed questionnaire | Race: Not reported | | | | 30–34 | 5.1
Age | Incontinence was defined as leaking urine twice or more a month. | Ethnicity: | | | | 35–39 | 6.6
Gender | | White: 98% | | | | 40–44 | 6.8
Social class | | Black Caribbean: 0.3% | | | | 45–49 | 10.4
Ethnicity | | Black other: 0.1% | | | | 50–54 | 7.5
Physical function | | Indian: 0.5% | | | | 55–59 | 10.1
Social function | | Pakistani: 0.1% | | | | 60–64 | 14.1
Mental health | | Chinese: 0.2% | | | | 65–69 | 10.6
Energy | | Other Asian: 0.1% | | | | 70–74 | 10.4
Pain | | Other: 0.7% | | | | 75–79 | 14.7
Health perceptions | | Residency: United Kingdom | | | | 80+ | 20.3
Level of evidence: III | | | | | | Total current incontinent | 9
| | | | | | Total ever incontinent | 23
Smoger, 2000 ^169^ | Male patients at primary care clinics (VA Medical Center), during a 14-week period. Investigators randomly selected morning or afternoon clinics and approached all patients seen within the selected clinic session. Response rate: 81.6% (n=809) | Age: | | | | Prevalence (Overall): 32,300/100,000 (32.3%)
Cross-sectional | Data source: anonymous, self-reported written survey without interviewer assistance. | Mean: 59.8 (Range: 25–93) | | | | By frequency:
Adjusted by: | Incontinence defined as, “Urine loss in the last 12 months.” | Gender: Male | | | | <1/month: 19,500/100,000 (19.5%)
Age | | Race: Not reported | | | | About 1/month: 4,700/100,000 (4.7%)
Ethnicity | | Ethnicity: | | | | <1/week: 3,300/100,000 (3.3%)
Prostate cancer | | White: 82.1% | | | | About 1/week: 6,800/100,000 (6.8%)
Prostate surgery | | African-American: 16.5% | | | | Almost every day: 7,000/100,000 (7%)
Bladder surgery | | Other: 1.4% | | | | By severity:
Diuretics | | Residency: Louisville, Kentucky | | | | Few drops: 19,500/100,000 (19.5%)
Antispasmodic agents | | | | | | Wet my underwear: 7,800/100,000 (7.8%)
Prostate active agents | | | | | | Wet outer clothing: 2,200/100,000 (2.2%)
Level of evidence: III | | | | | | Wet the floor: 700/100,000 (0.7%)
Smoger, 2000 ^169^ | investigators randomly selected morning or afternoon clinics and approached all patients in waiting room at primary care clinics in VA Medical Center over a 14-week period. Response rate: 81.6% (n=809) | Age: Mean: 59.8 | | | | Ethnicity | Prevalence %
Cross-sectional | Data source: self-reported written anonymous survey without assistance. | (Range: 25–93) | | | | White | 32
Adjusted by: | UI as, “Urine loss in the last 12 months.” | Gender: Male | | | | African-American | 33.1
Age | | Race: Not reported | | | | Other | 36.4
Ethnicity | | Ethnicity: | | | | Overall | 32.3
Prostate Cancer | | White: 82.1%
Prostate surgery | | African-American: 16.5%
Bladder surgery | | Other: 1.4%
Diuretics | | Residency: Louisville, Kentucky
Antispasmodic agents
Prostate active agents
Level of evidence: III
Temml. 2000 ^170^ | Subjects were selected from voluntary health examinations sponsored by the city of Vienna. The exams are regularly organized and are offered free of charge. | Age: ≥20 years | | | | Prevalence (Overall): Female: 26.3%, Male: 5.0%
Cross-sectional | Response rate: 100% (n=2,498) | (Mean age female: 49.7 SD: 13.6) | | | | By type (Of incontinent individuals):
Adjusted by:, Age, Gender | Data source: Self-reported questionnaires (based on Bristol LUTS questionnaire) | (Mean age male: 48.6 SD: 13.0) | | | | Female: Stress-92.0%, Urge-53.7%
Medical history, Concurrent medical therapies | Urinary incontinence was defined as, “Any involuntary loss of urine within the past 4 weeks.” | Gender: Male and Female | | | | Male: Stress-29.5%, Urge-53.4%
Weight, Height, BMI | | (Male: 49.5%) | | | | | Women% | Men%
Heart rate | | (Female: 50.5%) | | | | | (n . 332) | (n . 62)
Blood pressure | | Race: Not reported | | | | Stress incontinence | 92 | 29.5
Echocardiogram | | Ethnicity: Not reported | | | | Urge incontinence | 53.7 | 53.4
Marital status | | Residency: Vienna, Austria | | | | Post-void dribbling | 16.2 | 66.7
Cigarette smoking | | | | | | Nocturnal incontinence | 4.4 | 15.3
Alcohol consumption | | | | | | Pure stress incontinence | 39.8 | 5.9
Education | | | | | | Pure urge incontinence | 6.9 | 26.5
Sportive activities | | | | | | Pure nocturia | 0.4 | 0
Stress factors | | | | | | Pure post-void dribbling | 0 | 44.1
Level of evidence: III | | | | | | “Negative impact on quality of life:” Males-58.3%, Females-65.7% (incontinent individuals)
| | | | | | | Women% | Men%
| | | | | | | (n . 332) | (n . 62)
| | | | | | Not at all | 34.3 | 41.7
| | | | | | A little | 47.4 | 41.7
| | | | | | Moderate | 11.6 | 8.3
| | | | | | Severe | 6.7 | 8.3
| | | | | | By severity:
| | | | | | Frequency | Women% | Men%
| | | | | | | (n . 332) | (n . 62)
| | | | | | <1/week | 45.8 | 42.1
| | | | | | 2–3/week | 24.6 | 21.5
| | | | | | 1/day day | 10.5 | 10.9
| | | | | | >1/day | 21.1 | 20.3
| | | | | | Permanent | 1.8 | 1.9
Tseng, 2000 ^171^ | Subjects were randomly selected from elderly residents of Taiwan, residing in Tungkang. | Age: 65 years and older | | | | By gender | Prevalence %
Cross-sectional | Response rate: 80% (n=504) | Gender: Male and female | | | | Male | 15.0
Adjusted by: | Data source: Face to face interviews by registered nurses. | Male: 49.2% | | | | Female | 27.7
Age | Incontinence was defined as, “Inappropriate leakage of urine.” | Female: 50.8% | | | | Total | 21.6
Gender | | Race: Not reported | | | | By Type | % of incontinent subjects
Education | | Ethnicity: Not reported | | | | Stress | 30.7
Fitness | | Residency: Tungkang, Taiwan | | | | Urge | 30.7
Parity | | | | | | Mixed | 22.8
UI experience | | | | | | Undetermined | 15.8
UI perception | | | | | | Male
Treatment intention | | | | | | Age group | Prevalence %
Level of evidence: III | | | | | | <70 | 13.8
| | | | | | 70+ | 15.5
| | | | | | Female
| | | | | | Age group | Prevalence %
| | | | | | <70 | 24
| | | | | | 70+ | 29.9
Ueda, 2000 ^172^ | Subjects were selected from a random sample of 40–80 year olds living in 7 towns of Shiga Prefecture, Japan. | Age: 40–80 | | | | Prevalence: Overall
Cross-sectional | Response rate: 52.5% (n=1,836) | Gender: Male and female | | | | Male: 10.5%
Adjusted by: | Data source: self-reported, mailed questionnaires | Male: 46% | | | | Female: 53.7%
Age | Urinary incontinence was defined as a positive answer to the question, “Do you suffer from involuntary loss of urine?” | Female: 54%
Gender | | Race: Not reported
Stroke | | Ethnicity: Not reported
Angina | | Residency: Japan
Diabetes
Cystitis
Ability to change clothes
Ability to walk outside
Hysterectomy
Constipation
Level of evidence: III
Chiarelli, 1999 ^173^ | Randomly selected from national health insurance database, including all women in Australia. To increase the number of rural residents, oversampling of remote areas was done. Response rate: Youngest (18–23): 48%, Mid-age 45–50): 54%, Oldest (70–75): 41% | Age: | | | | Age group | Prevalence %
Cross-sectional study (Nested within a large randomized cohort known as the WHA project.) | Self-report survey questionnaires from WHA project. UI as, “Experiencing the leaking of urine in the last year”. Responses: never, rarely, sometimes, or often. | 35.4 % in youngest cohort (18–23) (n=14,761) | | | | 18–23: | 12.8
Confounding factors: Parity, Constipation, Other bowel problems, BMI, Urine that burns or stings, Surgery (In mid-age and older cohort) | | 33.7% in mid-age cohort (45–50) (n=14,070) | | | | 45–50: | 36.1
Level of Evidence: III | | 30.9% in oldest cohort (70–75) (n=12,893) | | | | 70–75: | 35
| | Gender: Women | | | | Prevalence: Overall-
| | Race/ Ethnicity: Not reported | | | | Youngest: 12,800/100,000 (12.8%)
| | Residency: Broadly representative of all States and Territories of Australia | | | | Mid-age: 36,100/100,000 (36.1%)
| | | | | | Oldest: 35,000/100,000 (35%)
| | | | | | The question asked “Did not allow differentiation between the different types of incontinence experienced by women, namely stress, urge, or mixed incontinence.”
Dolan, 1999 ^174^ | Subjects were randomly selected from a computerized register of family practice general practitioners living in four geographical areas of Northern Ireland. | Age: 35–74 | | | | Age | %
Cross-sectional | Response rate: 65.6% (n=689) | Gender: Female | | | | 35–44 | 56
Adjusted by: | Data source: Self-administered postal questionnaire | Race: Not reported | | | | 45–54 | 69
Age | Incontinence was defined as, “Leaking of urine within the past 2 years.” | Ethnicity: Not reported | | | | 55–64 | 55
Parity | | Residency: Northern Ireland | | | | 65–74 | 44
Employment status | | | | | | Total | 56.9
Pelvic floor exercises | | | | | | # of pregnancies | %
Gynecological operations | | | | | | 0 | 44
Level of evidence: III | | | | | | 1 | 47
| | | | | | 2 | 61
| | | | | | 3 | 64
| | | | | | 4 | 63
| | | | | | Total | 57.9
| | | | | | By Frequency | %
| | | | | | Sometimes | 33.5
| | | | | | Often | 23.4
Foldspang, 1999 ^175^ | Subjects were selected from the Danish Central Population Registry. Subjects were randomly selected and age-stratified. All subjects lived in the municipalities of Aarthus and Randers. | Age: 20–59 years of age | | | | Prevalence:
Cross-sectional | Response rate: 75.5% (n=4,710 respondents) | Gender: Female | | | | Overall: 17,700 / 100,000 (17.7%)
Adjusted by: | Data source: Mailed, self-administered questionnaire. | Race: Not reported | | | | Stress UI: 15,100 / 100,000 (15.1%)
Pregnancy | Women were asked, “Whether they had experienced urinary incontinence during the previous year.” If so, they were then asked whether the “episodes were generally provoked by physical stress or accompanied by a feeling of urge.” | Ethnicity: Not reported | | | | Urge UI: 8,700 / 100,000 (8.7%)
Vaginal childbirth | | Residency: Municipalities of Aarthus and Randers, Denmark. | | | | Mixed UI: 6,800 / 100,000 (6.8%)
Age at childbirth
Obstetric procedures
(Episiotomy, perineal suturing, forceps delivery, vacuum delivery)
Level of evidence: III
Damian, 1998 ^176^ | Subjects were randomly selected from community dwelling individuals ≥65 years, registered on the Madrid City Roll. | Age: ≥65 years. (n of each age group not reported) | | | | Prevalence:
Cross-sectional | Response rate: 71.2% | Gender: Male and female (n of each gender not reported) | | | | Overall: (15.5%)
Adjusted by: | Response by age group: | Race: Not reported | | | | By Gender:
Age | 65–74: 71.4% | Ethnicity: Not reported | | | | Male: (14.5%)
Gender | 75–84: 73.1% | Residency: All respondents are community dwelling residents of Madrid, Spain | | | | Female: (16.1%)
Marital status | 85 and over: 67.1% | | | | | Of those that are incontinent:
Education | Response by gender: | | | | | Urge: (26.6%)
Occupation | Males: 78.0% | | | | | Stress: (12.5%)
BMI | Females: 64.5% | | | | | Mixed: (16.1%)
Number of children + miscarriages | Data source: At home interviews by trained, gender-matched professionals. | | | | | Other: (15.5%)
Self-rated health | Incontinence was determined by a positive answer to the question, “Do you currently experience any difficulty in controlling your urine? In other words, does your urine escape involuntarily?” | | | | | Of those that are incontinent, by gender:
U.I. related chronic conditions | | | | | | Male Urge: (52.2%)
General mobility | | | | | | Male Stress: (10.6%)
Level of evidence: III | | | | | | Male Mixed: (16.1%)
| | | | | | Male Other: (21.1%)
| | | | | | Female Urge: (12.3%)
| | | | | | Female Stress: (13.5%
| | | | | | Female Mixed: (61.8%)
| | | | | | Female Other: (12.3%)
Koyama, 1998 ^177^ | Subjects from residents >60 years in 3 different communities. Questionnaires were distributed through the town or village office. | Age: 60 and older | | | | Prevalence: | In nursing home
Cross-sectional | Response rate: | Gender: male and female | | | | Overall: | Overall:
Adjusted by: | Rural: 98.4% (n=937) | Race: not reported | | | | Male: 4.7% | Male: 16.2%
Age | Suburban: 65% (n=934) | Ethnicity: Not reported | | | | Female: 11.3% | Female: 23.2%
Gender | Nursing home: Not reported (n=433) | Residency: Japan (Suburban, rural, and nursing home residents). | | | | By age:
Parity | Data source: Self reported questionnaires. In the nursing home, some subject data was obtained from the nurse or caregiver of the patient. | | | | | 60–69:
Living area | Incontinence as, “even a small amount of leakage at a time when there was no intention of urinating.” | | | | | Male: 0.7% | Male: 8.7%
Level of evidence: III | | | | | | Female: 7.9% | Female: 23.5%
| | | | | | 70–79:
| | | | | | Male: 6.3% | Male: 20.5%
| | | | | | Female: 10.2% | Female: 21.0%
| | | | | | 80+:
| | | | | | Male: 9.1% | Male: 15.8%
| | | | | | Female: 20.2% | Female: 24.6%
Koskimaki, 1998 ^178^ | Subjects were selected from all men born in 1924, 1934, and 1944 living in Tampere, Finland or one of the rural or semi-rural municipalities within the same county. Subjects were identified from the National Population Register. | Age: | | | | Age-adjusted prevalence:
Cross-sectional | Response rate: 68% (n=2,128) | 50: (38%, n=806) | | | | By type:
Adjusted by: | Data source: Self-reported mailed questionnaire | 60: (34%, n=732) | | | | Urge incontinence: 17,000 / 100,000 (17%)
Age | Incontinence was measured on a 4 item scale, from 0 points for no symptom to 3 points for severe symptoms. Urge incontinence, stress incontinence, and other incontinence were classified as mild when they were reported to occur rarely, and moderate to severe when occurring more often. | 70: (28%, n=590)) | | | | Stress incontinence: 9,000 / 100,000 (9%)
Level of evidence: III | | Gender: Male | | | | Other incontinence: 10,000 / 100,000 (10%)
| | Race: Not reported | | | | By severity:
| | Ethnicity: Not reported | | | | Urge incontinence:
| | Residency: Tampere, Finland | | | | Mild: 16,000 / 100,000 (16%)
| | | | | | Moderate/severe: 1,000 / 100,000 (1%)
| | | | | | Stress incontinence:
| | | | | | Mild: 8,000 / 100,000 (8%)
| | | | | | Moderate/severe: 1,000 / 100,000 (1%)
| | | | | | Other incontinence:
| | | | | | Mild: 9,000 / 100,000 (9%)
| | | | | | Moderate/severe: 1,000 / 100,000 (1%)
Kuh, 1999 ^179^ | Selected from participants in the Medical Research Council Survey of Health and Development. | Age: 48 years old | | | | | Prevalence %
Design: | Response rate: 93% (n=1,378)). | Gender: Female | | | | Severe | 8
Nationally representative prospective cohort. | Measured using a mailed self-administered questionnaire. | Race: Not reported | | | | Urge | 22.4
Confounders: | Definition of UI: | Ethnicity: Not reported | | | | Stress | 49.9
Childhood enuresis, Information on the data of the birth of children, Caesarian deliveries, BMI, Kidney or bladder infections, Menopausal status, Health status (Self-reported), Socioeconomic status | Severe as occurring ≥2/month in the previous year and reporting loss of more than a few drops of urine. | Residency: General population sample of women living in England, Scotland, and Wales. | | | | Overall | 54.8
Level of evidence: II-2B | Moderate as 1 but not both of the aforementioned symptoms. | | | | | By Impact on life | Prevalence %
| Mild or none at all: reporting milder symptoms or none at all. | | | | | Bothered a little | 15.5
| Stress as yes to: “Do you ever lose urine when you cough, sneeze, laugh, run, or exercise?” | | | | | Bothered a lot | 4.7
| Urge as yes to: “Do you ever have an urgent and strong desire to pass urine which is difficult to control?” and follow up question, “Do you ever lose any urine before you reach the toilet?”
Stenberg, 1999 ^180^ | Subjects were selected from all women born in a county in Sweden between December 1921 and January 1923 (71 year old group) as well as born between December 1911 and January 1913 (81 year old group). Names and addresses were obtained from the population register. | Subject age: | | | | Prevalence:
Cross-sectional | Response rate: | 71 years of age and 81 years of age | | | | Overall:
Adjusted by: | 87% (Of those aged 71) (n=1,084) | Gender: Female | | | | 71-year-old group: 46,000 / 100,000 (46%)
“Socio-demographic factors,” obstetrical and gynecological history, somatic diseases, previous surgery, previous fractures, current medications, and estrogen treatment | 62% (Of those aged 81) (n=611) | Race: Not reported | | | | 81-year-old group: 45,000 / 100,000 (45%)
Level of evidence: III | Data source: Mailed, self-reported questionnaire. | Ethnicity: Not reported | | | | Mixed incontinence:
| Definition of incontinence used in study not reported, but the article claims that the “questionnaire covered all urinary incontinence problems.” Symptoms were classified as, “none, trivial, moderate, severe, or unbearable.” | Residency: Uppsala County, Sweden | | | | 71-year-old group: 20,000 / 100,000 (20%)
| | | | | | 81-year-old group: 20,000 / 100,000 (20%)
| | | | | | Urge and stress UI prevalence not reported.
| | | | | | UI of considerate severity: (Symptoms were deemed considerate when the respondent marked, “moderate, severe, or unbearable” on their response sheet)
| | | | | | 71-year-old group: 48,000 / 100,000 (48% of those women experiencing urinary incontinence deemed their UI considerately severe. General population prevalence not reported. “N” not reported either.)
| | | | | | 81-year-old group: 59,000 / 100,000 (59% of those women experiencing urinary incontinence deemed their UI considerately severe. General population prevalence not reported. “N” not reported either.)
Swithinbank, 1999 ^181^ | Women ≥19 years registered at a general practice were selected and mailed a questionnaire. The practice was chosen because it had near average social and demographic patterns for the city. | Age: 52 (Mean), 19–97 (Range) | | | | Prevalence:
Cross-sectional | Response rate: 80% | Gender: Female | | | | Overall: 69,000/100,000 (69%)
Adjustment factors not reported. | Data source: Validated, self-completed questionnaire. | Race: Not reported | | | | By Type:
Level of evidence: III | Incontinence defined using the Bristol Female Lower Urinary Tract Symptoms questionnaire (BFLUTS), asking about symptom occurrence during the previous month with a five point likert scale; the 2nd part asks about the degree to which the symptom causes a problem, on a 4-point scale. This definition of UI, was not reported in the article. | Ethnicity: Not reported | | | | Stress incontinence: 60,000/100,000 (60%)
| | Residency: a major British city(Not identified in article). | | | | Urge incontinence: 46,000/100,000 (46%)
| | | | | | Impact on life:
| | | | | | Incontinence having a social or hygienic impact (as per ICS definition of incontinence): 30,000 / 100,000 (30%)
| | | | | | Of those women reporting incontinence, 61% reported that it was “problematic.” (61,000/100,000)
| | | | | | Overall, 40% of women surveyed reported that they experienced incontinence that was “problematic.” (40,000/100,000)
Jitapunkul, 1998 ^182^ | Selected from all elderly persons living in the Klong Tuey slum in Thailand. Response rate: 72.6% (n=114) | Age 60+ (Mean: 69.3) | | | | Prevalence: Overall: 16.2%
Cross-sectional | Data source: At home interviews | Gender: Male and female | | | | Male: 10.8% | Female: 18.9
Adjusted by: Age, Gender | Incontinence as: “During the last 12 months, does urine ever drip unexpectedly without your being able to stop it and you get wet?” | (Male: 33%, Female 67%) | | | | By type, Stress: Overall: 2.84
Marital status, Literacy | | Race: Not reported | | | | Male: 0.43 | Female: 4.03
Work and Perceived health status | | Ethnicity: Asian | | | | By type, Urge: Overall: 9.53
Life satisfaction | | Residency: Thailand | | | | Male: 7.33 | Female: 10.62
Level of evidence: III | | | | | | By type, Mixed: Overall: 2.13
| | | | | | Male: 1.72 | Female: 2.33
Roberts, 1998 ^183^ | Random individuals ≥ 50 years in Olmsted County, MN. Selected using records from the Rochester Epidemiology Project. There was a separate cohort for men and for women. A third cohort included men ≥40 years. | Gender: Male and Female | | | | Prevalence:
Cross-sectional | Response rate: 66% (n=1,540) | Age: ≥50 years 3rd cohort of men ≥40 years. | | | | Male 50+ Cohort: (24.3%)
Adjusted by: | Data source: Self-reported, validated questionnaires (incontinence as), “In the last year ” - “Were there any days when you leaked more than a few drops of urine?” - “If yes, how many days did you leak more than a few drops of urine?” - “ Have you had slow leakage or dribbling throughout the day?” - “Have you had leakage when you coughed or sneezed?” “When leakage has occurred, were you aware of the need to urinate before the leakage occurred?” Response options: never, l<25%, >25%, and >75% | Race: Not reported | | | | Female 50+ Cohort: (48.7%)
Age | | Ethnicity: Not reported | | | | Male 40+ Cohort: (17.3%)
Gender | | Residency: Olmsted County, MN | | | | By type:
Self-rated health status | | | | | | Women:
Level of evidence: III | | | | | | Stress incontinence: (13.2%)
| | | | | | Urge incontinence: (5.4%)
| | | | | | Mixed incontinence: (77.9%)
| | | | | | Neither stress nor urge (3.4%)
| | | | | | Men:
| | | | | | Stress incontinence: (3.5%)
| | | | | | Urge incontinence: (40.8%)
| | | | | | Mixed incontinence: (24.9%)
| | | | | | Neither stress nor urge: (30.8%)
| | | | | | By severity:
| | | | | | Men:
| | | | | | Mild: (77.8%)
| | | | | | Moderate/severe: (22.2%)
| | | | | | Women:
| | | | | | Mild: (69.7%)
| | | | | | Moderate/severe: (30.3%)
Talcott, 1998 ^184^ | Subjects were selected from August 1990-May 1994 from men seeking physician advice on early prostate cancer. Patients needed a tissue diagnosis of adenocarcinoma of the prostate, a radionuclide bone scan free of metastatic cancer, and no prior surgery or radiotherapy for prostate cancer to be eligible. All study enrollments occurred at Harvard Medical School, although treatments often occurred elsewhere. | Age: | | | | Prevalence of incontinence:
Prospective cohort study | Response rate: 72% (n=279) | Mean: 64.6 | | | | Baseline and by treatment:
Adjusted by: | Data source: Initial self-reported questionnaire. Medical records. Follow-up questionnaires at 3 and 12 months. | Median: 65 | | | | Prostatectomy:
Age | Incontinence was defined as “dribbling or leaking” and also by the use of “absorptive pad worn in the past week.” | Range: 41–86 | | | | 64 or less: 2,000 / 100,000 (2%)
Marital status | | Gender: Male | | | | 65 or more: 3,000 / 100,000 (3%)
Employment status | | Race: Not reported | | | | Radiotherapy:
Income | | Ethnicity: Not reported | | | | 64 or less: 0 / 100,000 (0%)
Education | | Residency: USA | | | | 65 or more: 1,000 / 100,000 (1%)
Radiotherapy | | | | | | At 3 months:
Radical prostatectomy | | | | | | Prostatectomy:
Sexual dysfunction | | | | | | 64 or less: 24,000 / 100,000 (24%)
Level of evidence: II-2A | | | | | | 65 or more: 24,000 / 100,000 (24%)
| | | | | | Radiotherapy:
| | | | | | 64 or less: 0 / 100,000 (0%)
| | | | | | 65 or more: 2,000 / 100,000 (2%)
| | | | | | At 12 months:
| | | | | | Prostatectomy:
| | | | | | 64 or less: 9,000 / 100,000 (9%)
| | | | | | 65 or more: 15,000 / 100,000 (15%)
| | | | | | Radiotherapy:
| | | | | | 64 or less: 0 / 100,000 (0%)
| | | | | | 65 or more: 2,000 / 100,000 (2%)
| | | | | | By severity (Absorptive pad worn in the past week):
| | | | | | Baseline and by treatment:
| | | | | | Prostatectomy:
| | | | | | 64 or less: 2,000 / 100,000 (2%)
| | | | | | 65 or more: 3,000 / 100,000 (3%)
| | | | | | Radiotherapy:
| | | | | | 64 or less: 0 / 100,000 (0%)
| | | | | | 65 or more: 2,000 / 100,000 (2%)
| | | | | | At 3 months:
| | | | | | Prostatectomy:
| | | | | | 64 or less: 57,000 / 100,000 (57%)
| | | | | | 65 or more: 61,000 / 100,000 (61%)
| | | | | | Radiotherapy:
| | | | | | 64 or less: 0 / 100,000 (0%)
| | | | | | 65 or more: 6,000 / 100,000 (6%)
| | | | | | At 12 months:
| | | | | | Prostatectomy:
| | | | | | 64 or less: 35,000 / 100,000 (35%)
| | | | | | 65 or more: 36,000 / 100,000 (36%)
| | | | | | Radiotherapy:
| | | | | | 64 or less: 0 / 100,000 (0%)
| | | | | | 65 or more: 7,000 / 100,000 (7%)
Bogren, 1997 ^185^ | Swedish population from a Primary Health Care District, SW Sweden, 54000 people in this area 458 persons, 65yrs and older | 225 women | | | | Prevalence = 28% women, 9% men p<.0001
Prospective cohort | questionnaire mailed to home - history of UI defined as involuntary voiding of urine, type of UI | 233 men | | | | 33% women reported sig. more SI than men 10% p <.05 as well as more Urge Incontinence 66% than men 40% p<.05
Level of evidence: | 76% response rate after 1^st^ mailing, 1^st^ reminder answered by 14% and 2^nd^ by 6%. | Prevalence of UI, gender differences
| | Women% men % p neuro disease 3%
| | 10% | | | NS
| | diabetes | | | 5
| | heart dis. | | | 7
| | 14
| | back pain | | | 52%
| | 57%
| | current UTI | | | 34
| | 10 | | | <.05
| | surgery bladder | | | 5
| | 14
| | surgery genital | | | 43
| | 14 | | | <.05
| | diuretics | | | 15
| | 14
| | sedatives | | | 8
| | 5
| | hypnotics | | | 20
| | <.05
| | sex hormones | | | 36
Brandeis, 1997 ^186^ | Subjects were selected from a representative sample of Medicaid-certified American nursing homes, drawn from ten states. A random sample of residents was selected from each of the 270 nursing homes studied. | Age: Residents 60 years of age or older | | | | Prevalence of urinary incontinence:
Cross-sectional | Response rate: 92.6% (n=2,014) | Mean: 84.3 (SD: 8.7) | | | | Overall: 49,000 / 100,000 (49%)
Adjusted by: | Data source: Standardized forms called the Minimum Data Set (MDS). Registered nurses were trained on data collection using that form. Data was collected from chart review, interview with nursing home staff, and observation of residents. | Gender: Male | | | | Men: 45,100 / 100,000 (45.1%)
Age | Incontinence was defined as, “at least two episodes per week of involuntary urine loss within the past two weeks.” | (24.5%) and female | | | | Women: 78,400 / 100,000 (78.4%)
Gender | | (75.5%) | | | | Type, severity, and impact of incontinence not reported.
Race | | Race:
Anti-depressant use | | White: 81.9%
Impaired mobility | | Black: 12.7%
ADL's | | Other not reported
Specific diseases (fecal impaction, CHF, UTI, diabetes, pedal edema, delirium, dementia) | | Ethnicity: Not reported
Level of evidence: III | | Residency: Nursing home residents in ten states in the USA
Brieger, 1997 ^187^ | Subjects were randomly selected from telephone directories in the regions of Hong Kong Island, Kowloon, and the New Territories. | Age: Mean: 45 (SD: 15) | | | | Prevalence:
Cross-sectional | Response rate: 43% | Gender: Female | | | | Overall: 13,000 / 100,000 (13%)
Adjusted by: | Data source: Telephone survey with a previously validated and tested questionnaire. | Race: Not reported | | | | By Type:
Age | Incontinence was defined as “involuntary loss of urine which is socially or hygienically unacceptable.” | Ethnicity: Chinese | | | | Stress Incontinence: 10,000 / 100,000 (10%)
Height | | Residency: Hong Kong, China | | | | Urge Incontinence: 700 / 100,000 (0.7%)
Weight
BMI
Place of birth
Parity
Employed
Constipation
Smoking
Level of Evidence: III
Malmsten, 1997 ^188^ | Subjects were randomly selected from the total population of men 45 and older living in Goteborg, Sweden in 1992. The subjects were selected from the population register, and were selected by year of birth. Several cohorts were obtained at 5-year intervals. A sample was taken from those born in: 1947, 1942, 1937, 1932, 1927, 1922, 1917, and 1912. All men born in 1907 or earlier were included to obtain a more comprehensive sample of older men. | Age: ≥45 years | | | | Age (years) | Prevalence %
Cross-sectional | Response rate: 74% (n=7,763) | Mean: 63.1 (SD: 19.0) | | | | 45 | 3.6
Adjusted by: | Data source: Self-reported, mailed questionnaire | Gender: Male | | | | 50 | 4.1
Age | Urinary incontinence was defined according to the International Continence Society and was confirmed by a 48-hour pad test and voiding lists. | Race: Not reported | | | | 55 | 3.3
Marital status | | Ethnicity: Not reported | | | | 60 | 5.1
Foreign extraction | | Residency: Goteborg, Sweden | | | | 65 | 6.1
Place of residence | | | | | | 70 | 7.3
Urinary tract infections | | | | | | 75 | 9.6
Level of evidence: III | | | | | | 80 | 19.7
| | | | | | 85–89 | 21.8
| | | | | | 90+ | 28.2
| | | | | | Total | 9.2
| | | | | | Overall: 9,200 / 100,000 (9.2%)
| | | | | | By severity (Of incontinent men):
| | | | | | Daily leakage: 64,100 / 100,000 (64.1%)
| | | | | | 2–3 times/week: 12,600 / 100,000 (12.6%)
| | | | | | Once weekly: 8,200 / 100,000 (8.2%)
| | | | | | Once monthly: 15,100 / 100,000 (15.1%)
| | | | | | By impact on life:
| | | | | | Men who considered their UI to “Limit their social life:” 31,000 / 100,000 (31%)
Mozes, 1997 ^189^ | Subjects were randomly selected from all Israeli cities and settlements over 5,000. Areas were stratified by region and population size. Within selected cities, the sampling unit was according to dwelling. Within dwellings, individuals were recruited using quotas for socioeconomic status and age. | Age: 45–75 years old | | | | Prevalence:
Adjusted by: | Response rate: 93.3% (n=896) | Gender: Male | | | | Stress Incontinence: 2,100 / 100,000 (2.1%)
Age | Data source: Personal interviews in homes of respondents with a validated questionnaire. | Race: (Listed as “origin” in report) | | | | By Severity: (Of any urinary symptoms, which include: weak stream, frequency, hesitancy, dribbling, dysuria, incomplete emptying, nocturia, stress incontinence, urinary retention)
Origin | This study looked at “urinary symptoms.” The only question dealing specifically with incontinence was, “Do you experience involuntary urination while coughing or laughing?” Stress incontinence was the only type of incontinence measured. | Asia-Africa: 43.2% | | | | Bothersome:
Education | | Europe-America: 47.7% | | | | Mild: 86,500 / 100,000 (86.5%)
Economic status | | Israel: 9.1% | | | | Moderate: 8,900 / 100,000 (8.9%)
Urinary symptoms | | Ethnicity: Not reported | | | | Severe: 4,600 / 100,000 (4.6%)
Co-morbidities (Heart disease, diabetes, respiratory disease, hypertension, joint disease, peptic disease, renal disease, cancer) | | Residency: Israeli cities and settlements
Level of evidence: III
Nakanishi, 1997 ^190^ | Subjects were randomly selected from all residents of Settsu, Japan aged 65 or older. Subjects were identified from a computerized age/sex register. | Age: 65 and older | | | | Male | Daily or more
Cross-sectional | Response rate: 95.4% (n=1405) | Gender: Male and Female | | | | 65–74 | 0.3
Adjusted by: | Data source: At home interviews | Race: Not reported | | | | 75–84 | 1.2
Gender | Incontinence was determined by a positive response to the question, “Do you wet or soil yourself?” | Ethnicity: Not reported | | | | 85+ | 0
Age | | Residency: Settsu, Japan | | | | Male | Less than daily
General health status | | | | | | 65–74 | 0.5
Stroke | | | | | | 75–84 | 7.9
Diabetes | | | | | | 85+ | 9.7
Dementia | | | | | | Female | Daily or more
Social activity | | | | | | 65–74 | 0
Anxiety | | | | | | 75–84 | 1.8
“No life worth living” | | | | | | 85+ | 3.4
Level of evidence: III | | | | | | Female | Less than daily
| | | | | | 65–74 | 2.2
| | | | | | 75–84 | 6.4
| | | | | | 85+ | 8.5
Samuelsson, 1997 ^191^ | Subjects were selected from all women scheduled for a gynecological health examination by midwives in a primary health care district during one year. Subjects were mailed a questionnaire if they were between 20–59. Exclusions were women who were pregnant or lactating, had a cervical smear in the last year, or who had mental retardation. | Age: Subjects were 20–59 years of age. | | | | Prevalence:
Cross-sectional | Response rate: 77% (n=491) | By age group: | | | | Overall: 27,700 / 100,000 (27.7%)
Adjusted by: | Data source: Self-reported postal questionnaire. | 20–29: 153 | | | | By type:
Age | Urinary continence was defined as a positive answer to the question, “Do you suffer from involuntary loss of urine?” Stress incontinence was defined as, “leakage during effort,” and urge incontinence was defined as, “leakage with sense of urge.” Mixed incontinence was the presence of both. Unspecific incontinence was defined as, “leakage, but not during effort or with sense of urge.” | 30–39: 118 | | | | Stress incontinence: 15,700 / 100,000 (15.7%)
Marital status | | 40–49: 87 | | | | Urge incontinence: 2,000 / 100,000 (2%)
Education | | 50–59: 133 | | | | Mixed incontinence: 5,300 / 100,000 (5.3%)
Work status | | Gender: Female | | | | Unspecific incontinence: 4,700 / 100,000 (4.7%)
Smoking | | Race: Not reported | | | | By severity:
Coffee consumption | | Ethnicity: Not reported | | | | Daily leakage: 3,500 / 100,000 (3.5%)
History of disease and medication, including HRT | | Residency: Sweden | | | | Once a week: 4,900 / 100,000 (4.9%)
Parity | | | | | | Once a month: 4,100 / 100,000 (4.1%)
Obstetric history | | | | | | Seldom: 15,200 / 100,000 (15.2%)
Menopausal age
Gynecological symptoms
Gynecological operations
Level of evidence: III
Schulman, 1997 ^192^ | Subjects were selected randomly using a sampling technique based on the Multi Method Multi Stage program. Quotas were established based on age, sex, and profession. | Age: | | | | Prevalence:
Cross-sectional | Response rate: 89% (n=5,269) | 30–34: 699 (13.3%) | | | | Overall: 10,900 / 100,000 (10.9%)
Adjusted by: | Data source: Self-completed questionnaires | 35–49: 1,792 (34%) | | | | By Gender:
Age | Urinary incontinence was determined by participant's responses to the following: “Arriving too late to the toilet” (urge incontinence), “losing urine when laughing or coughing too much” (stress incontinence), “continuously losing some urine” (permanent incontinence), “losing some urine after micturition” (postmicturition incontinence). | 50–64: 1,478 (28%) | | | | Male: 5,200 / 100,000 (5.2%)
Gender | | 65+: 1,299 (24.7%) | | | | Female: 16,300 / 100,000 (16.3%)
Parity | | Gender: | | | | By type (Based on persons who are incontinent) Stress incontinence: 42,000 / 100,000 (42%)
Professional status | | Male: 2,499 (47.4%) | | | | Male: Not reported
Level of evidence: III | | Female: 2,770 (52.6%) | | | | Female: 53,000 / 100,000 (53%)
| | Race: Not reported | | | | Urge incontinence: Overall not reported
| | Ethnicity: Not reported | | | | Male: 45,000 / 100,000 (45%)
| | Residency: Belgium residents | | | | Female: 55,000 / 100,000 (55%)
| | | | | | By severity (Based on persons who are incontinent):
| | | | | | Considered “bothersome:” 30,000 / 100,000 (30%)
| | | | | | Considered “more or less bothersome:” 70,000 / 100,000 (70%)
| | | | | | Permanent incontinence: 3,500 / 100,000 (3.5%)
| | | | | | Several daily episodes: 17,400 / 100,000 (17.4%)
| | | | | | One episode a day: 8,500 / 100,000 (8.5%)
| | | | | | 2–3 weekly episodes: 18,600 / 100,000 (18.6%)
| | | | | | 2–3 monthly episodes: 34,500 / 100,000 (34.5%)
| | | | | | No response: 17,500 / 100,000 (17.5%)
Thom, 1997 ^193^ | Subjects were selected from a random sample of women aged 60 years and older who were members of Kaiser Permanente Medical Care Plan of Northern California. | Age: Mean: 69.6 (SD: 7.0) | | | | Prevalence:
Adjusted by: | Response rate: 74.7% | Gender: Female | | | | Overall: 72,600 / 100,000 (72.6%)
Age | Data source: Self-reported, mailed questionnaire | Race: | | | | By type:
Race | Incontinence was defined as “at least one episode of incontinence in the past 12 months.” Stress incontinence was, “incontinence triggered by one or more activities associated with increased intra-abdominal pressure, with leakage usually occurring immediately and without a sense of urgency.” Urge incontinence was defined as, “experiencing a sense of urgency prior to the incontinence.” Those with both types had mixed incontinence. | White: 77% | | | | Stress: 16,900 / 100,000 (16.9%)
BMI | | Hispanic: 5% | | | | Urge: 23,900 / 100,000 (23.9%)
Parity | | Black: 8% | | | | Mixed: 23,600 / 100,000 (23.6%)
Hysterectomy before age 45 | | Asian: 6% | | | | Other: 8,300 / 100,000 (8.3%)
Estrogen replacement | | Other: 5% | | | | By Severity:
Parturition variables (parous women only) | | Ethnicity: Not reported | | | | Less than once/month: 14,300 / 100,000 (14.3%)
Level of evidence: III | | Residency: Northern California | | | | Monthly: 23,900 / 100,000 (23.9%)
| | | | | | Weekly: 21,800 / 100,000 (21.8%)
| | | | | | Daily: 12,200 / 100,000 (12.2%)
Brown, 1996 ^194^ | From population-based listings in 4 areas, previously participating in a study on osteoporotic fractures. | Age: 70+ | | | | Prevalence %
Cross-sectional | Response rate: Not reported (n=7,949) | Mean: 76.9 (SD: 5.0) | | | | Overall | 41.3
Adjusted by: Age, Menopausal status, Hysterectomy, BMI, Poor health, COPD, Stroke, Diabetes, CHF, Parkinson, Oral estrogen, Diuretics, Coffee, Smoking, Alcohol consumption, Exercise, Gait speed, Muscle strength | Data source: interview, self report questionnaire, and physical exam. | Gender: Female | | | | Severity | Prevalence %
Level of evidence: III | UI as, “During the last 12 months, have you ever leaked or lost control of your urine?” | Race: Not reported | | | | Daily | 14.2
| | Ethnicity: Not reported | | | | Infrequent | 27.1
| | Residency: Baltimore, Minneapolis, Monongahela Valley by Pittsburgh, and Portland, USA | | | | Total | 41.3
Umlauf, 1996 ^195^ | Selected from men ≥55 years enrolled in a hospital based senior citizens group. | Age: ≥52 years (Mean: 71.6) | | | | Prevalence:
Cross-sectional | Response rate: 28% (n=1,490) | Gender: Male | | | | Overall: 29%
Adjusted by: Age, Ethnicity Functional status Prostate problems Surgery, Diuretic use Caffeine use, Nocturia Symptoms of urinary retention | Data source: Mailed, self-reported questionnaires | Race: Not reported | | | | By age: | By severity:
Level of evidence: III | Incontinence was defined as, “Uncontrolled urine leakage during the month before the survey.” | Ethnicity: White, Black, Latino, Other | | | | 52–64: 19.7% | Mild: 86.4%
| | Residency: USA | | | | 65–74: 26.1% | Moderate: 9.1%
| | | | | | 75–84: 38.1% | Severe: 4.5%
| | | | | | 85–94: 31.4%
| | | | | | 95–99: 66.7%
Seim, 1995 ^196^ | Subjects were selected from all women ≥20 years. | Age: 20 years and older | | | | Prevalence %
Cross-sectional | Response rate: 77% (n=1,820) | Gender: Female | | | | Overall | 29
Adjusted by: Age | Data source: Self-reported mailed questionnaires | Race: Not reported | | | | By type | % of incontinent subjects
Level of evidence: III | Incontinence was defined as, “Any frequency or amount of leakage.” | Ethnicity: Not reported | | | | Stress | 48.8
| | Residency: Rural community, Rissa Norway | | | | All other types | 51.2
| | | | | | Severity | % of incontinent subjects
| | | | | | Slight or moderate | 64.7
| | | | | | Severe | 24%
| | | | | | Unknown | 11.3
Kutner, 1994 ^197^ | Selected from data provided by the National Institute on Aging, in cooperation with FICSIT and NCNR (community dwelling elderly persons). (n=352) | Age: Mean: 77.1 | | | | Prevalence:
Cross-sectional | Response rate: Not reported | Gender: Male and Female | | | | Overall:
Adjusted by: Age, Gender Marital status, Ethnicity, Education Cognitive functioning Depression Chronic health conditions | Baseline data from the Frailty and Injuries: Cooperative Studies of intervention study. | Race: Not reported | | | | Male: 4.5%
Level of evidence: III | Incontinence as “≥1episodes/week of loss of urine control.” | Ethnicity: Not reported | | | | Female: 17.9%
| | Residency: USA
Mommsen, 1994 ^198^ | Subjects were selected from an age-stratified random sample of women 30–59. Response rate: 84.5% (n=2,631) | Age: 30–59 years | | | | Prevalence:
Cross-sectional | Data source: Self-reported, mailed questionnaire. | Gender: Female | | | | Overall: 17%
Adjusted by:, Age, BMI, Menopausal status, Parity Abdominal or gynecologic surgery Cystitis, Occupation | Incontinence as, “Experiencing UI during the year 1987.” | Race: Not reported | | | | By Type:
Level of evidence: III | | Ethnicity: Not reported | | | | Stress: 15%
| | Residency: Aarhus. Denmark | | | | Urge: 9%
| | | | | | Mixed: 7%
Brocklehurst, 1993 ^199^ | Randomly selected in 3 geographically stratified points. | Age: 30 years and older | | | | Male:
Cross-sectional | Response rate: Not reported (n=4,007) | Gender: Male and female | | | | Age category | Prevalence: Ever | Previous year | Previous 2 months | Previous week
Adjusted by: | Data source: home interviews by trained interviewers. | Male: 47% | | | | 30–49 | 2 | 1.5 | 0.8 | 0.8
Age | UI as yes to question about “bladder problems e.g. leaking, wet pants, damp pants.” | Female: 53% | | | | 50–59 | 5.4 | 2.5 | 2.5 | 2.5
Sex | | Race: Not reported | | | | 60+ | 13.3 | 7.3 | 5.3 | 3.7
Recency of symptom | | Ethnicity: Not reported | | | | Total | 6.6 | 3.8 | 2.8 | 2.2
Level of evidence: III | | Residency: Great Britain | | | | Female:
| | | | | | Age category | Prevalence: Ever | Previous year | Previous 2 months | Previous week
| | | | | | 30–49 | 10.9 | 7.2 | 5.4 | 3.6
| | | | | | 50–59 | 15.4 | 9.1 | 6.3 | 5.2
| | | | | | 60+ | 16.8 | 11.7 | 10.2 | 8.3
| | | | | | Total | 14 | 9.3 | 7.5 | 5.7
Lagace, 1993 ^200^ | Selected from all ≥20 years seeking health care for any reason at 5 family practices during an 11 week period. Response rate: 77.8% (n=2,830) | Age: ≥20 years | | | | Prevalence: 33%
Cross-sectional | Data source: Self-reported, anonymous questionnaire | Gender: Male and female | | | | By gender:
Adjusted by: | UI as, “Any degree of incontinence in the past 12 months.” | Race/ ethnicity: Not reported | | | | Male: 11% Female: 43%
Age | | Residency: Upper Peninsula Research Network of Michigan) | | | | By impact on life: Considered a “Social or hygienic problem” (For purposes of the investigators, this was also considered “Significant” in terms of severity):
Gender | | | | | | Male: 5% Female: 23%
Level of evidence: III
Milsom, 1993 ^201^ | Subjects were randomly selected from all women in the city of Goteborg, Sweden using the population register. Women were sampled from birth cohorts 1900, 1905, 1910, 1915, 1920, 1930, and 1940. | Age: 46–86 years old | | | | Birth cohort | | Prevalence %
Cross-sectional | Response rate: 74.6% (n=7,459) | Gender: Female | | | | 1900 | | 24.6
Adjusted by: | Data source: Self-reported mailed questionnaires. | Race: Not reported | | | | 1905 | | 22.1
Age | Incontinence was defined as, “inappropriate leakage of urine,” and was validated by a sub sample of women by objectively confirming by a 48 hour pad test, micturition lists, and a cough provocation test. | Ethnicity: Not reported | | | | 1910 | | 17.5
Parity | | Residency: Goteborg, Sweden | | | | 1915 | | 15.1
Oral contraception | | | | | | 1920 | | 13.9
Hysterectomy | | | | | | 1930 | | 12.1
Menopausal status | | | | | | 1940 | | 12.1
Level of evidence: III | | | | | | Birth cohort 1930
| | | | | | Yrs Oral Contraception | | Prevalence
| | | | | | 0 | | 11.5
| | | | | | 1–3 | | 13.9
| | | | | | 4–6 | | 11
| | | | | | 7+ | | 14
| | | | | | Parity
| | | | | | 0 | | 7.7
| | | | | | 1 | | 11.1
| | | | | | 2 | | 13.1
| | | | | | 3+ | | 14
| | | | | | Premenopausal | | 13
| | | | | | Postmenopausal | | 10.1
| | | | | | Birth cohort 1940
| | | | | | Years Oral Contraception | | Prevalence
| | | | | | 0 | | 11.3
| | | | | | 1–3 | | 15.3
| | | | | | 4–6 | | 7.5
| | | | | | 7+ | | 10.7
| | | | | | Parity
| | | | | | 0 | | 5.5
| | | | | | 1 | | 10.6
| | | | | | 2 | | 12.1
| | | | | | 3+ | | 16.4
| | | | | | Premenopausal | | 11.6
| | | | | | Postmenopausal | | 12
| | | | | | Birth cohort | Hysterectomy | Prevalence %
| | | | | | 1900 | Y | 32.3
| | | | | | | N | 22.8
| | | | | | 1905 | Y | 27.1
| | | | | | | N | 21.8
| | | | | | 1910 | Y | 24.5
| | | | | | | N | 16.7
| | | | | | 1915 | Y | 18.3
| | | | | | | N | 14.7
| | | | | | 1920 | Y | 15.6
| | | | | | | N | 13.5
| | | | | | Total | Y | 20.8
| | | | | | | N | 16.4
Kok, 1992 ^202^ | Subjects were recruited from women ≥60 years. A random sample of 30 women born each year was obtained from the population register. | Age: 60 years and older | | | | Age group | Prevalence %
Cross-sectional | Response rate: 69% (n=719) | Gender: Female | | | | 60–64 | 20
Adjusted by: | Data source: Self administered postal questionnaires. | Race: Not reported | | | | 65–69 | 19
Age | Incontinence as, “Involuntary loss of urine at least twice a week.” | Ethnicity: Not reported | | | | 70–74 | 16.8
Mobility | | Residency: Amstelveen, Netherlands | | | | 75–79 | 22.7
Frequency | | | | | | 80–84 | 26.5
Nocturia | | | | | | 85–89 | 30.8
Urgency | | | | | | 90+ | 28.4
Fecal incontinence | | | | | | Overall | 23.5
Level of evidence: III
Rekers, 1992 ^203^ | Subjects were selected from a stratified sample of women drawn from the Bureau for Population Registration in the Netherlands. | Age: 35–80 | | | | | Pre-menopausal | Post-menopausal
Cross-sectional | Response rate: 67.7% (n=1,299) | Gender: Female | | | | Prevalence
Adjusted by: | Data source: Self-reported, mailed questionnaires | Race: Not reported | | | | (Overall) | 25.1 | 26.4
Age | “Serious incontinence was defined as incontinence occurring at least once a week and in larger amounts than a few drops of urine. All other incontinence was deemed to be minor.” | Ethnicity: Not reported | | | | Frequency:
Marital status | | Residency: Zoetermeer, Netherlands | | | | <1/month | 7.5 | 7
Menopausal status | | | | | | >1/month-<1/week | 6.7 | 5.1
Genito-urinary symptoms | | | | | | >1/week-<1/day | 7.8 | 7.2
Pelvic area surgery | | | | | | >1/day | 3.1 | 7.1
Vaginal deliveries | | | | | | Amount lost:
Level of evidence: III | | | | | | Drops only | 12 | 13.4
| | | | | | A little | 11.1 | 12
| | | | | | A lot | 2 | 1
| | | | | | Type:
| | | | | | Stress | 5.9 | 5.1
| | | | | | Urge | 3.9 | 4.5
| | | | | | Mixed | 11.1 | 13
| | | | | | Unknown | 4.2 | 3.8
Burgio, 1991 ^204^ | Subjects were selected from participants in the University of Pittsburgh Healthy Women Survey, a 5-year prospective study. Participants were recruited from women with driver's licenses in selected zip codes of the Pittsburgh area. | Age: Mean: 47 years | | | | Prevalence %
Prospective cohort | Response rate: 60% (n=541) | Gender: Female | | | | Overall | 58.4
Adjusted by: BMI, Parity Race, Caffeine intake Alcohol intake, Smoking Physical activity, Age | Data source: Nurse administered interview questionnaire | Race: | | | | Stress | 47.9
Menopausal status | Incontinence was defined as, “Ever leaked even a small amount of urine involuntarily.” | White: 90.6% | | | | Mixed | 35.8
Hysterectomy | | Other (Not reported): 9.4% | | | | Urge | 11.7
Gynecological surgery | | Ethnicity: Not reported | | | | Uncategorized | 4.6
Level of evidence: II-2B | | Residency: Pittsburgh, USA | | | | Frequency | Prevalence %
| | | | | | Never | 41.6
| | | | | | <1/month | 26.7
| | | | | | >1/month | 13.4
| | | | | | >1/week | 10.5
| | | | | | Daily | 6.8
Ju, 1991 ^205^ | Selected from all residents, ≥65 years living in a public housing estate. Data obtained from the National Registry Department. | Age: 65+ | | | | Prevalence: Overall: 4.6%
Cross-sectional | Response rate: 80.4% (n=919) | Gender: Male and female | | | | Male: 4.4% | Female: 4.8%
Adjusted by: | Data source: At home interviews | (Male: 47.3%, Female: 52.7%) | | | | By age group:
Age | Incontinence was defined as, “Leakage of urine 2 or more times in the past month.” | Race: Not reported | | | | 65–69: 3.1% | 70–74: 3.2%
Gender | | Ethnicity: | | | | 75–79: 6.7% | 80–84: 8.4%
Ethnicity | | Chinese: 83.5% | | | | 85+: 9.8%
Level of evidence: III | | Malay: 9.7% | | | | By ethnicity:
| | Indian: 6.6% | | | | Chinese: 5.2% | Malay: 1.1%
| | Eurasians: 0.2% | | | | Indian: 1.6% | Eurasian: 0%
| | Residency: Singapore | | | | By type:
| | | | | | Pure urge: 1.3% | Mixed: 0.3%
Lagro-Janssen, 1990 ^206^ | Selected from 2,400 randomly selected practice files of 75 general practitioners. Response rate: 60% (n=1,442) | Age: 50–65 | | | | | Prevalence %
Cross-sectional | Data source: Self reported data from home interviews conducted by trained interviewers. | Gender: Female | | | | Overall | 22.5
Adjusted by: Age, Marital status, Parity, Education, Employment Perceived health status, Hypertension, Diabetes, COPD, Obesity, Varicose veins, CHF Symptoms of loco motor system Hysterectomy | Urinary incontinence defined as, “involuntary loss of urine more than twice a month.” No attempt was made to classify based on type. | Race: Not reported | | | | By Severity:
Level of evidence: III | | Ethnicity: Not reported | | | | None | 77.5
| | Residency: Eastern Netherlands | | | | Mild | 8
| | | | | | Moderate | 7.8
| | | | | | Severe | 6.7
Molander, 1990 ^207^ | Subjects were selected from a random sample of women born in 1900–1920 at five-year intervals in the city using the population register. Response rate: 70.1% (n= 4,206) | Age: 65–84 years | | | | Birth cohort | 1900 | Prevalence % | 24.6
Cross-sectional | Data source: Self-reported, mailed questionnaires UI definition on the mailed form was not reported. However, the first 300 women to report UI were invited to attend a clinic where UI was confirmed by detailed medical history, examination, a 48 hour pad test, micturition lists, and a cough provocation test. | Gender: Female | | | | | 1905 | | 22.1
Adjusted by: | | Race: Not reported | | | | | 1910 | | 17.5
Age | | Ethnicity: Not reported | | | | | 1915 | | 15.1
Urinary tract infections | | Residency: Goteborg, Sweden | | | | | 1920 | | 13.9
Other urogenital symptoms | | | | | | Total | | | 16.9
Estrogen treatment | | | | | | Frequency | | % of incontinent women
Level of evidence: III | | | | | | Daily | | | 55.6
| | | | | | 2–3 times/week | | | 13.2
| | | | | | 1/week | | | 5.4
| | | | | | 1–3 times/month | | | 18.9
| | | | | | By Type | | % of incontinent women
| | | | | | Stress | | | 24
| | | | | | Urge | | | 49
| | | | | | Mixed | | | 27
Herzog, 1990 ^41^ | Subjects all non-institutionalized persons ≥60 years in a stratified probability sample. | Age: 60 years and older | | | | Gender | Baseline prevalence
Prospective cohort | Response rate: 66% (n=1,956) | Gender: Male and female | | | | Male | 18.80%
Adjusted by: | 1 year follow-up: 69% | Males: 41% | | | | Female | 37.70%
Age | 2 year follow-up: 72% | Females: 59% | | | | | Prevalence at 1 year
Sex | Data source: At home interviews by interviewers trained at the U of Michigan School of Public Health. | Race: Not reported | | | | Male | 19.2
General health status | UI as, “any uncontrolled urine loss within the previous 12 months.” | Ethnicity: Not reported | | | | Female | 48.7
Level of evidence: II-2C | | Residency: Washtenaw County, Michigan | | | | | Prevalence at 2 years
| | | | | | Male | 29.7
| | | | | | Female | 56.7
Lagro-Janssen, 1990 ^206^ | Subjects were selected from 2,400 randomly selected practice files of 75 general practitioners. | Age: 50–65 | | | | Prevalence: 22.5%
Cross-sectional | Response rate: 60% (n=1,442) | Gender: Female | | | | By impact on life:
Adjusted by: Age, Marital status, Parity, Education, Hysterectomy, Employment, Perceived health status, Hypertension, Diabetes, COPD, Obesity, Varicose veins, CHF, Symptoms of loco motor system | Data source: Self reported data from home interviews conducted by trained interviewers | Race: Not reported | | | | “Not worried about it”: 77.8%
Level of evidence: III | UI defined as, “involuntary loss of urine >2/month.” | Ethnicity: Not reported | | | | By severity:
| No attempt was made to classify based on type. | Residency: Eastern Netherlands | | | | Mild: 8.0%
| | | | | | Moderate: 7.8%
| | | | | | Severe: 6.7%

Multiple logistic regression of ‘long term’ UI and delivery mode history ^67^

Variable | Incontinence Total | N | % | Odds ratio | (95% CI) | P
Delivery mode history
All other histories | 2,707 | 1263 | (46.7) | 1.0 | Reference
Only caesarean section(s) | 435 | 141 | (32.4) | 0.50 | (0.40–0.63 | 0.001
Any forceps | 1,029 | 480 | (46.6) | 0.96 | (0.83–1.11 | 0.567
Maternal age at first birth
<25 | 1,432 | 568 | (39.7) | 1.0 | Reference | 0.001
25–29 | 1,697 | 766 | (45.1) | 1.34 | (1.15–1.55 | 0.001
30–34 | 835 | 427 | (51.1) | 1.88 | (1.57–2.25 | 0.001
>35 | 207 | 123 | (59.4) | 2.98 | (2.18–4.07 | 0.001
Number of births
One | 528 | 202 | (38.3) | 1.0 | Reference | 0.001
Two | 2,202 | 993 | (45.1) | 1.30 | (1.07–1.59 | 0.001
Three | 1,025 | 490 | (47.8) | 1.61 | (1.29–2.02 | 0.001
Four or more | 416 | 199 | (47.8) | 1.73 | (1.31–2.27) | 0.001
Number of women | 5 4171
Number symptomatic | 5 1884
Symptoms are yes at 6 years

Table F1d Prevalence and incidence of fecal incontinence in adults

Author, Year, Design, Adjustment for Confounding Factors | Subject Selection, Data Source, Methods to Measure Incontinence (survey, screening, case finding), Definition of incontinence) | Subject Age, Gender, Race, Ethnicity, Residency | Prevalence (%) or Incidence of Fecal Incontinence, Overall: by Type, Severity, and Impact on Life
Uustal Fornell, 1996 ^208^ | 51 Females with rupture of anal sphincter during vaginal delivery. | Age: | Incontinence of Liquid Stool
Comparative case control | 31 Females without rupture of anal sphincter during vaginal delivery, rupture groups were subdivided into incomplete sphincter rupture and complete sphincter rupture for some analyses. | Gender: Female | 16% of the 51 with a rupture
| Methods: Questionnaires at 6 months after delivery. | Residency: Sweden | 13% of the 31 without a rupture
| Definition: 6 point scale, 6= complete continence, 1 = total incontinence, incontinence of gas, liquid stool, solid stool, soiling, no operational definitions were given. | | Liquid Stool on the 6 Point Scale
| | | Unable to determine median severity score for no rupture group
| | | Median severity for incomplete rupture group = 5
| | | Median severity of liquid stool incontinence for complete rupture group = 4.5
| | | Solid Stool = 0% per test
| | | (These results above are presented by box plots)
Pescatori, 1990 ^209^ | 207 patients who underwent restorative proctocolectomy and ideoanal reservoir between March 1980 and May 1989 who were in the Italian registry, 156 patients where studied. | Age: <45 years (n=123) >45 years (n=33) | Fecal Soiling:
Prospective, observational | Definition: Disordered continence, occasional soiling of mucus or feces, permanent soiling of mucus or feces, total minor leak, total major leak. | Residence: Italy | Soiling in those <45 years old=6% of 123
Adjustment For: No determination of whether patients had fecal incontinence pre-operatively was reported. | None of these were operationally defined; “totals” appear to be mucus and feces | | Soiling in those >45 years old=15% of 33
| | | Bivariate analysis of risk, n = stool frequency. Pouchitis
| | | 70 patients with fecal soiling, of those with <5 stools/day = 4%, n = 4 of 108
| | | 70 patients with fecal soiling, of those with >5 stools/day = 17% (n = 8)
| | | Pouchitis: 22% (4/18) patients who had pouchitis had fecal soiling while 6% of those without pouchitis (8/138) had fecal soiling.
| | | No significant difference in any risk.
Belmonte-Montes, 2000 ^210^ | 98 primiparous females of obstetrics out-patient clinic of medical specialties, Center of Mexican army and air force between May of 1996-1999. | Age: Average = 22.4 years | Fecal Incontinence
Prospective, descriptive, observational | Methods: Interview, clinical exam, and endo-anal ultrasound that were done 4–6 weeks before and 6 weeks after delivery. | SD = 3.56, range = 16–34 | 21 had some fecal incontinence after delivery but gas and mucus leaks are mixed in here so not included.
Adjustment For: Females with a history of anal sphincter damage, diabetes, neurological disease, needing a C section, or history of previous anarectal or vaginal surgery were excluded. | Definition: Incontinence of gas, mucus, liquid and solid stool, frequency ≥1 × 1 week, ≥2 × 1 month, 1 × 1 month | Gender: all Female | “Major” fecal incontinence later defined as “accidental bowel movements” was in 5 women.
| | Residency: Mexico | Risks: 14 women with a sphincter defect on ultrasound had fecal incontinence but 7 did not. Results state there was a strong association between sphincter defect on ultrasound and incontinence. P <.0001 but no “r” or other statistic is reported.
Ho, 1995 ^211^ | 602 consecutive patients who had a curative resection for colorectal cancer ≥12 months prior to survey. | Age: x = 64.5 years, SEM = .7 | No overall % was reported.
Cross section | Methods: mailed questionnaire. | Gender: F = 41.3%, M = 58.7% | After R hemicolectomy: Grade 3 = 16.4% of 55 patients
Listed as not eligible | Definition: used grading classification, grade 3 = occasional liquid soiling, 4 = frequent liquid or mild soiling, 5 = incontinence of solids. | Residency: Singapore | After L hemicolectomy: Grade = 9.6%, Grade 5 = 1.9% of 53 patients
| | | Sigmoid colectomy: Grade 3 = %.4%, Grade 5 = 3.6% of 56 patients
| | | Low anterior resection: Grade 3 = 19.9%, Grade 4 = 5%, Grade 5 + 4.3% of 143 patients
O'Keefe, 1995 ^212^ | Random sample of 704 Olmsted County residents ≥ 65 years old 530 responded, 478 completed section containing fecal incontinence information | Age: x = 75 years, range = 65–98 | Fecal incontinence
Cross sectional | Method of Measurement- mailed survey. | Gender: 49% female | Overall + 8.2% (5.5, 10.8), 95% CI
Adjustment For: data were adjusted to age and gender specific proportions in 1980, US census | Definition: fecal incontinence as leakage of stool once per week or more or use of a pad to prevent soiling. The second part of the definition doesn't require leaking, only an intent to prevent it. | Residency: Olmsted County, MN | Men = 8.1 % (4.3, 11.8)
| | | Female = 7.9 (4.4, 11.4)
| | | Impact on life
| | | Functional status and health of those with fecal incontinence did not differ from those with any of the GI condition and did not appear to be significantly different from controls (no p values given).
| | | Other Findings: 16% of those with diarrhea had fecal incontinence, 12% of those with IBS had fecal incontinence, no denominators were reported
Hinds, 1990 ^213^ | Every 4th person on mailing list of National MS Society of Allegheny County, 78 persons in Allegheny hospital work force non MS controls. | Age: 280/with MS 339 responded, 78 non MS, age MS = 48 years (19–77), non MS = 42 years (22–64) | Prevalence of Fecal Incontinence
Point prevalence | Methods: mailed questionnaire, 1 follow up mailed questionnaire to MS patients with fecal incontinence | Gender: Female = 77% of MS, Female = 78% non MS | Overall MS = 51%
| Definition: Involuntary passage of stool at least once during preceding 3 months | Residency: Allegheny County PA | Mild MS = 25%
| | | Non MS = 4%
| | | 50/147 MS patients responded to follow up: Fecal incontinence occurred most often when stools were semi-formed as liquid (no data reported)
| | | Fecal incontinence frequency: daily = 2%, 1 to several times a week = 22%, ≤1/week - 7.33 months = 23%, once every 3 months = 50%
Kok, 1992 ^202^ | 1049 questionnaires were mailed to women ≥60 years in Amstelveen, Netherlands; a random sample of 30 women born each year was selected | Age: 60–84 years | Fecal Incontinence; <85 = 4.2% of 625, ≥85 = 16.9%
Survey, point prevalence | Methods: Mailed survey | Gender: Female | Urinary Incontinence; daily = 14% (n = 96)
| Definition: Occasional involuntary loss of feces | Residency: Amstelveen, Netherlands | 60–85 years, fecal incontinence = 8 (8.5%) of those with urinary incontinence, fecal incontinence = 11 (2.9%) of those without urinary incontinence
| | | ≥85 years, fecal incontinence = 9 (21.4%) of those with urinary incontinence, fecal incontinence = 15 (12.2% of those w/o urinary incontinence.
Talley, 1992 ^214^ | Age and sex stratified random sample of non-institutionalized residents in Olmsted Country MN aged 65–93 years. | Age: not reported | Fecal Incontinence; Once/week = 3.7% (1.6–5.9)
Survey, point prevalence | Methods: mail questionnaire | Gender: not reported | 1/ week and needs to wear a pad = 7% (4.1–9.9) wear a pad for fecal incontinence- 6.1% (3.3–8.8) Of the 7%:
Adjustment For: age and sex adjusted using 1980 US white population | Definition: Stool leakage; clinical significant incontinence was defined as once a week or more, or if wearing a pad is needed | Race and Ethnicity: all white | Fecal Incontinence and constipation w/o obstructive features = 4%
| | Residency: Olmsted County, MN | Fecal incontinence and constipation with obstructive features = 17%
| | | Fecal Incontinence and diarrhea = 42%
| | | Fecal Incontinence without constipation or diarrhea = 42%
| | | Age Adjusted Women:
| | | Fecal Incontinence >once/week = 3.1 (.39–5.9)
| | | Fecal Incontinence and pad = 6.7% (2.9–10.6)
| | | Age Adjusted Men:
| | | Fecal Incontinence >once/week = 4.5% (1.3–7.7)
| | | Fecal Incontinence and pad = 4.6% (1.4–7.8)
Hojberg, 2000 ^215^ | All women getting routine antenatal cure at Aarhus University Hospital from January 1993–April 1996. 7,557 completed questionnaire | Age: 15–24 years = 1302 | Fecal Incontinence:
Cross sectional | Methods: Questionnaire | (17%), 25–29 = 3162 | Liquid Stool = 2.3%
| Definition: fecal incontinence as involuntary loss of flatus, liquid, or solid stool in the past year. | (42%), 30–34 = 2292 | Solid Stool = .06%
| | (30%), 735 = 801 (11%) | Note- Multiple logistic regression was done for flatus incontinence only
| | Gender: all female
| | Residency: Denmark
Faltin, 2001 ^216^ | All women who attended the maternity outpatient clinics at Geneva University Hospital in Switzerland from August 1st to September 30th, 1996. 1,228 responded | Age: not reported for whole sample | Fecal Incontinence
Cross sectional | Methods: Structured questionnaire | Gender: All female | M = 38 had solid or loose stools: 38/99 who had any anal incontinence = 38%, 38/1228 = 3%
| Definition: fecal incontinence as involuntary loss of solid or loose stools or flatus occurring ≥once/month, asked to report type of incontinence: flatus and/or liquid and/or solid stool | Residency: Switzerland | Note: 8% of the 1228 respondents had any anal incontinence
Kirk, 1997 ^217^ | 171, patients with spinal cord injury ≥1 year duration. | Age: x = 39.5 years, SD = 14.5, range= 18–81 years | Incontinence
Cross sectional | Source: discharge list from acute rehabilitation, inpatient facility and an advertisement in newsletter of local chapter of National Spinal Cord Injury Association. | Gender: 75% male, n = 128 | 30% had incontinence in the past month
Adjustment For: stratified sampling by duration of spinal cord injury, 1–5 years spinal cord injured = 85 points, 75 years = 86 points | Methods: phone survey | Residency: United States | 65% had incontinence in the past year (only a bar graph reported findings, no exact percentage was given)
| Definition: the inability to control bowel elimination to achieve voluntary, predictable, and spontaneous fecal evacuation. | | Total number of incontinence problems per month is x = .9, SD = 2.9, median = 0, range = 0–30
| Paraplegics = 47.4% (n = 81), tetraplegics = 52.6% (n = 90)
Curless, 1994 ^218^ | 273 with colorectal CA selected consecutively from 2 hospitals' histology records and surgical admission lists since 1989. 273 controls matched for sex and age ± 2 years, from the general practitioner's register; unrelated to cases, excluded for colorectal adenoma, carcinoma or inflammatory bowel disease. | Age: median age overall = 68 years, Range = 25–93 years. | Fecal Incontinence
Cross sectional comparison of cases and controls | Methods: Interview | 123 cases (45%) ≥70 (“old”), 125 controls (46%) ≥70 years, “young” <70years | 27/150 patients of young cases (< 70)
| Definition: none reported | Gender: 153 males/120 females in each group | 0/148 patients of young controls
| | Race: all white | 23/123 of old cases
| | Residency: England | 8/125 of old controls
| | | Odds ratio (95% confidence interval) for young cases versus controls = 32.3 (8.5, 121.9); for old cases versus controls = 3.4 (1.5, 7.6)
Enck, 1991 ^219^ | 138 controls, employees of government office in Dusseldorf without any symptoms per a questionnaire in past month. Patient groups considered at risk for fecal incontinence were consecutive patients with lower gastrointestinal complaints suggestive of carbohydrate mal-absorption referred for hydrogen breath testing; N = 29, x age = 39, N = 16; consecutive patients with inflammatory bowel disease in outpatient clinic, N = 108, x age = 31.2 years, N = 39; consecutive patients with diabetes from inpatient and outpatient clinic of diabetes research institute; type 1 diabetes, N = 90, x age = 32.6, N = 41; Type 2 diabetes, N = 109, x age = 62.4, N = 47 | Age: controls × age = 37.7 years, range = 19–60 years | Fecal Incontinence
| Methods: Questionnaire | Gender: sex of controls male = 73, female = 65 | Controls with any fecal incontinence = 5% (m = 7), >mild fecal incontinence = (1.4% m = 2)
| Definition: Uncontrolled loss of stool during day or uncontrolled loss of stool during night, or fecal soiling. 1 of the 3 needed, if only fecal soiling fecal incontinence considered “mild”. | Residency: Germany | Inflammatory bowel disease with any fecal incontinence = 28% (n = 31), >mild fecal incontinence = 12.9% (n = 14)
| | | Type 1 diabetes with any fecal incontinence = 1.1% (m = 1), >mild fecal incontinence = 1.1% (m = 1)
| | | Type 2 diabetes with any fecal incontinence = 11% (m = 12), >mild fecal incontinence = 4.5% (n = 5)
| | | Lower gastrointestinal patients with any fecal incontinence = 20% (n = 33), >mild fecal incontinence = 9.7% (n = 16)
| | | Upper gastrointestinal patients with any fecal incontinence = 20.7% (n = 6), >mild fecal incontinence = 6.9% (n = 2)
| | | any fecal incontinence in inflammatory bowel disease vs. controls p = .001, >mild fecal incontinence
Franssen, 1997 ^220^ | 784 Patients in an ongoing study of aging and Alzheimer's disease. | Age: Median age = 72.2, SD =9.5 | Permanent Double Incontinence 9.6% of females and 5% of males
Cross sectional | Source: Findings are from the most recent evaluation regardless of baseline or follow up | Gender: N = 283 and F = 501 | Of the 244 normals (fast score 1 and 2) or mildly impaired (fast score 3 and 4) none had double incontinence.
Adjustment For: Patients who developed a stroke during follow up were excluded | Methods: Interview | Race: 90% Caucasian (N = 709), 8% African American (N = 63), 1,5% = other (N = 12) | Of the 470 who had Alzheimer's (fast score 4–7) 13% had permanent double incontinence.
| Definition: Incipient incontinence-urinary incontinence and/or fecal incontinence that is increasingly apparent but not yet permanent or needing assistance by a caregiver in toileting to prevent incontinence. | Residency: United States
| Note: Results did not separate urinary incontinence only from findings so incipient incontinence is ineligible to be included. Permanent double incontinence = score of 7a or greater on fast scale meaning always doubly incontinent without external intervention.
Fine, 1997 ^221^ | 78 patients with celiac sprue treated with a gluten free diet ≥12 months, 11 patients who qualified agreed to further studies | Age: x and median age = 52 years, range = 19–77 years | 1/11 patients had fecal incontinence
Cross sectional | Methods: Mail survey or telephone interview, patients who reported having diarrhea were asked to undergo further study | Gender: 59 female, 19 male
| Definition: Self report of fecal incontinence by history or inability to hold a liquid enema | Residency: Texas, United States
Oberwalder, 2006 ^222^ | Patients who underwent anal sphincter repair between 1988 and 2000 and had 3 months of follow-up, N= 131, 38 had external anal sphincter and internal anal sphincter defects, 93 had external anal sphincter defect only | Age: EAs and IAs = 48.3 years | Incontinence Score = 16.1 in external anal sphincter and internal anal sphincter group.
Cross sectional, retrospective | Methods: Medical record review | Gender: All female | IS = 16.7 in EAs only, group not significant.
| Definition: Fecal Incontinence-Cleveland Clinic, Florida, incontinence score- 0 = continent, 20 = completely incontinent, score 0–10 = post-operatively success, 11–20 = post-operatively failure | Residency: United States | No significant difference in fecal incontinence success rate post-operatively.
| | | 68.4% had success in external anal sphincter and internal anal sphincter group.
| | | 55.9% had success in external anal sphincter group.
Rose, 2002 ^223^ | 150 patients undergoing laproscopic or laproscopic assisted surgery for rectal prolapse in 1995 | Age: Range- 52–91 years, Females = 64.5 ± 11.3 | Pre-operatively m = 46 (30.7%)
Cross sectional | Definition: “Incontinence” since problem is rectal prolapse and would assume fecal incontinence. | Gender: 131 females
Campbell, 1990 ^224^ | Residents >65 years in statutory residences (n = 157), voluntary residential homes (n = 60), private residence home (n = 55), private nursing home (n = 94), hospital geriatric continuing care words (n = 141) | Age: 70% were ≥80 years and more than half of these were ≥85 years | Incontinence
Cross sectional | Methods: Survey | | Statutory residence; 0 = 55.6%, 1 = 32.7%, 2 = 11.8%
| Definition: (type unspecified) 0 = no disability, 2 = maximum disability. | | Voluntary residential homes; 0 = 85%, 1 = 10%, 2 = 5%
| | | Private Residence; 0 = 69.1%, 1 = 21.8%, 2 = 9.1%
| | | Private Nursing Home; 0 =55.3%, 1 = 12.8%, 2 = 31.9
| | | Hospital Wards; 0 = 13.5%, 1 = 14.9%, 2 = 71.9%
Klotz, 2002 ^225^ | Tetraplegic spinal cord injured patients participating in a multicenter epidemiological study who are ≥16 years at injury and ≥18 years at survey | Age: (at survey) = 43.6 (13.5) ×(SD) | Urinary incontinence
Cross sectional | Methods: Survey | Gender: M = 80% | none = 44% (m = 700), sometimes = 37% (m = 589), often = 18.9% (m = 301)
| Definition: “Have you had any embarrassing bowel leakages?” (never/sometimes/often) “Have you ever had any awkward urinary leakages?” (never/sometimes/often) | Residency: France | Fecal Incontinence
| | | None = 63.5% (m = 1016), sometimes = 32% (m = 512), often = 4.5% (m = 72%)
Marcello, 1993 ^226^ | Patients who had construction of an ileo-anal pouch from 6180–12191 N = 460 | Age: mean (SD) = 31 (9) | Incidence of fecal incontinence
Cohort | Methods: Interview at office visit or buy phone and mail questionnaire | Gender: Male = 251 (55%) | Overall fecal incontinence after 1 year = 10% (m = 31)
| Definition: “leakage” is reported, no question re: fecal incontinence is reported that was used in interview or questionnaire | | Fecal incontinence 1–3 months after surgery = 18% of 395 patients, 1–3 years after surgery = 10% of 326 patients, > 5 years after surgery = 17% of 137 patients
| | | 58% (n = 18) patients soiled only at night
| | | Frequency of leakage occurred 3 ± 2 days per week.
| | | Note: Pre-operative fecal incontinence was not reported
Giordano, 2002 ^227^ | 151 women who had anterior over lagging repair because of obstetric injury, 115 had no previous repair, 36 had a previous repair | Age: median = 46 years, Range = 20–68 years | Incidence of fecal incontinence
Cohort | Methods: telephone, interview or mail questionnaire | Gender: Female | No previous repair (n = 115), pre-operative incontinence score = 18, postoperative incontinence score = 5 (p < .0001)
| Definition: Cleveland Clinic Florida fecal incontinence score, incontinence score between 0–5 = “good” outcome, 6–10 = “adequate”, 11–20 = “poor” outcome | Residency: United States (Florida) | Previous repair, pre-operative incontinence score = 17.5, post-op incontinence score = 7 (p <.0001)
| | | Duration of incontinence in mos. (unclear whether incontinence is preoperative or post-operative in those with previous repair)
| | | No previous repair group = 96.5 (1–456) mos.
| | | Previous repair group = 60 (6–468 mos.) median (range)
Mazouni, 2005 ^228^ | Primiparas who underwent instrumental childbirth delivery, N = 159 responded to questionnaire about fecal incontinence. | Age: 29.4 years | Incidence of Fecal Incontinence
Cohort | Methods: Questionnaire by mail or telephone interview | Gender: Female | New fecal incontinence = 8.8%
| Definition: Solid and/or liquid stool incontinence buy question on questionnaire was not reported. | Ethnicity: African = 13.2%, European = 59.8%, Maghreb = 27%
| | Residency: France
Guenin, 2005 ^229^ | Patients who had conventional hemorrhoidectomy between 1/1/93 – 12/31/97, N = 514 | Age: x= 52 years | Prevalence of fecal incontinence
Cohort | Methods: Record review then mail questionnaire for fecal incontinence | Range 22–96 years | Fecal incontinence light in 86 (21.2%)
| Definition: Question and answer on survey “Do you have loss of feces (soiling)?” Not present, light, moderate, or severe | Gender: 195 females | Moderate in 25 (6.1%)
| | | Severe in 4(.98%)
| | | No fecal incontinence in 291 (71.7%)
Tocchi, 2004 ^230^ | 164 patients treated for chronic anal fissure with surgery | Age: x= 37 years | Fecal Incontinence
Cohort | Methods: Interview and physical exam | Range 18–44 years | Early fecal soiling occurred in 15 patients (19.1%). Continence was restored within 3 months in 12/15 patients.
| Definition: No definition of fecal incontinence was reported, “early” fecal incontinence- present within 1 month after surgery and spontaneously resolved, “late” fecal incontinence- occurred after 1 month after surgery and required some type of corrective procedure | Gender: 93 males | Note: there is no report of pre-operative continence status
| | Residency: Italy
Wagenius, 2003 ^231^ | 218 women with a history of obstetric anal sphincter rupture and repair between 1994-1999, 436 women with no rupture | Age: Median(range) = for total n (534) = 29(18–42) years, cases n = 186 = 30(18–40) years, controls m = 348 = 29(18–42) years | Urinary Incontinence
Retrospective case-control | Methods: mail questionnaire | Gender: All female | Cases = 24 (13%), Controls = 33 (9%)
Adjustment: Case and controls matched for age parity, vaginal delivery birth weight, and year of birth | Definition: no definition reported | Residency: Sweden | Not significant OR(ci) = 1.41(.81–2.47)
| | | Fecal incontinence of liquid stools
| | | Cases = 39 (21%), Controls = 26 (7%) p < .0001, 3.29 (1.93–5.6)
| | | Fecal incontinence of solid stool
| | | Cases = 8 (4%), Controls = 8 (2%)
| | | Not Significant = 1.91 (.71–5.170)
Quander, 2005 ^232^ | Chicago Health and Aging Project = 6,099, 1993-1997 time period. | Age: 65–74 years = 59%, 75–84 years = 30%, >85 years = 11% | Fecal Incontinence in 585 (9.6%)
Cross sectional | Methods: In-home interview. | Gender: 61% female | Multivariate analysis (logistic regression) adjusting for age, sex, and race, fecal incontinence = 1.7 times greater in diabetics vs. non-diabetics (ci = 1.4, 2.1) and 2.8 times greater in stroke vs. non-stroke residents (ci = 2.2, 3.5)
| Definition: Interview question and answer = “In the past few months, have you ever lost control of your bowels when you didn't want to?” | Subject Race and Ethnicity: 62% Black, N = 6 American Indian, N = 9 Pacific Islander, N = 41 Hispanic | Medication use adjusted for sex, age, race, history of diabetes and stroke in multivariate analysis.
| | Residency: United States | Antidepressants, 21% using, 1.9(1.2, 3.0)
| | | Antipsychotics, 33% using, 3.9(2.5, 6.2)
| | | Narcotics, 17% using, 1.7(1.2, 2.5)
| | | Hypnotics, 26% using, 3.1(1.8, 4.8)
| | | Antiparkinson, 33% using, 4.3(2.5, 3
| | | Anticonvulsant, 22% using, 1.9(1.9, 3.2)
| | | Income and Education and Fecal Incontinence Prevalence
| | | Fecal incontinence income < $10,000 = 14.3%, $10,000-$20,000 = 8.6%, > $20,000 = 6.8%, xˆ2 = 65.5 p <.0001
| | | Fecal incontinence in people with 0–8 years education = 12.9%, 9–12 years education = 8.8%, >13 years education = 8.7%, xˆ2 = 19 p <.0002 “No significant difference in prevalence of fecal incontinence in men vs. women once adjusted for age”.
| | | “In prevalence of fecal incontinence with age was greater among blacks than whites (p = .0006)”.
| | | Among those 85 years and older, fecal Incontinence in white females = ~17%, white Males = 19%, black females = 24%, black Males = 16%.
| | | Fecal incontinence in stroke patients = 21.5%, No stroke = 8.3% p < .0001, diabetics = 13.2%, Non-diabetics = 8.8%.
Schweitzer, 2005 ^233^ | 128 women who had surgery for pelvic organ prolapse. | Subject Age: N = 112 women ≥80 years, responded (88%), x(range) = 83(80–92) years | Urinary Incontinence
Retrospective, descriptive | Source: 3 hospitals | Gender: Female | Strenuous urinary incontinence = 14% (12/87)
| Methods: postal questionnaire | Residency: Netherlands | Urge urinary incontinence = 10%
| Definition: no definition reported; findings report urinary incontinence after surgery | | Mixed urinary incontinence = 31%
| | | No urinary incontinence = 40%
| | | Unknown = 5%
| | | Note: 36% n = 46 patients had “incontinence” before surgery
Sangalli, 2000 ^234^ | 448 women who had a partial (30) or complete (40) tear during delivery between January 1982 and December 1983, 178 responders; 129 had 3rd degree tear, 49 had 4th degree tear | Age: x = 27.7 years in 1982/83, in 1995 age = x = 40.7 years, range = 32–54 years | Fecal Incontinence
Retrospective, descriptive, and cohort | Methods: Telephone interview >10 years after delivery | Gender: Female | Of the 129 with 3 degree tears, 6.2% (n = 8) had fecal incontinence of liquid stools and 0.8% (n = 1) had fecal incontinence of solid stools
| Definition: fecal incontinence response was recorded only if the women perceived the incontinence as bothersome | Residency: Switzerland | Of the 48 with the 4 degree tears, 10.2% (n = 5) had fecal incontinence of liquid stools and 6.1% (n = 3) had fecal incontinence of solid stools
| | | All were non-significant
Siproudhis, 2005 ^235^ | 10,000 people ≥15 years received a household survey in May–June 2003, N = 7,196 responded, 2,915 had anorectal problems | Subject Age: mean age(SD) = 45.8(23.1) years, 2,388 <35 years, 2,332 >54 years 1,440 ≥65 years (20%) | Fecal incontinence = 513/2,915 (17%), 513/7,196 (7.1%)
Cross sectional | Methods: mail questionnaire. | Gender: 3,455 males | Usual stool consistency in those with fecal incontinence.
| Definition: (question and answer) “During the past 12 months have you ever experienced an uncontrolled anal leakage of stool?” Quality of life = 10cm visual analog scale for professional life, social life, sexual/partner life, family life | Residency: France | Loose = 18%, Hard = 20%, Very hard = 5%, Normal = 15% (findings reported in graph only)
| | | Stool consistency of people with fecal incontinence differed from those without any anorectal problems, p <.01
| | | Usual stool consistency in those with no problems
| | | Loose = 7%, Hard = 3%, Normal = 50%
| | | Frequency of Fecal Leakage
| | | ≥1/day = 11 (2.2%) 1/day to 1/week = 25 (4.8%), 1/week to 1/month = 41 (8%), <1/month = 420 (82%), not applicable = 15 (2.9%)
| | | Quality of life for “incontinence” includes gas and stool leakage so unable to determine effect of fecal incontinence on quality of life.
Buchanan, 2002 ^236^ | N= 79, 418 admission MDS forms of Nursing Home residents with Parkinsons's disease from June 23, 1998 – September 12, 2000 | Age: x = 79.7 years, SD = 9.0 | Prevalence of fecal incontinence = 48%
| Methods: MDS data | Gender: 48.4% male | Prevalence of urinary incontinence = 39%
| Definition: MDS items for bladder and bowel incontinence | Subject Race: white = 89.4%, black = 5.1%, Asian = 1.4%, American Indian = 4% | Frequent urinary incontinence = 16.8%,
| | | Occasional urinary incontinence = 9.8%
| | | Frequent fecal incontinence = 8.6%
| | | Occasional fecal incontinence = 6.5%
Stenzelius, 2007 ^237^ | N = 248, age ≥ 75 years | Subject Age: x = 82, SD = 5.19 | Fecal Incontinence.
Cross sectional | Methods: Postal questionnaire to people who reported they had fecal incontinence in past 3 months on a different (previous) questionnaire. | Gender: Female = 142, Male = 106 | Fecal Incontinence in 56.4% of respondents.
| Definition: No definition reported | Residency: Sweden | Daily/weekly fecal incontinence:
| | | Women = 18.6%
| | | Men = 4.9% (p = .01)
| | | Overall = 12.8% non-significant
| | | Large or medium amount of fecal incontinence: Women = 18.2
| | | Men = 6%, p = .01
| | | Overall = 43.6% non-significant
| | | Fecal incontinence did not have significant impact on quality of life.
Sullivan, 1992 ^238^ | N = 109 runners who ran an average of 18 miles per week in a runners club; inclusion criteria was running 3 times per week. | Age: 39 ± 13 Male, 34 ± 9 Female | Fecal Incontinence in 12% (n = 13) 10 males, 3 females during or after running
Cross sectional | Methods: Questionnaire. | Gender: Male = 78, Female = 31
| Definition: none. | Residency: Canada
Otegbayo, 2006 ^239^ | Consecutive patients with stroke selected over 18 months (N = 54), controls = normal, volunteers or inpatients (N = 46) without fecal incontinence. | Age: Stroke patients = 58.7 (10.6) control = 52(10.9) | Prevalence of Fecal Incontinence
Cross Sectional | Methods: Interview or chart. | Gender: Stroke male = 46.3%, control male = 69.6% | Stroke = 5.6%
| | Residency: Africa | Control = 0%
| | | P = .10
| | | No difference in % fecal incontinence by type of stroke (ischemic vs. hemorrhagic, p = .20) or right vs. left side of brain with stroke p = .51
Ween, 1996 ^240^ | Consecutive admissions of stroke patients to Braintree Hospital in 1993; N = 423 | Age: 73 ± 12 | Prevalence of incontinence
Cross Sectional | Methods: Chart review | Gender: 55% female | 41% were incontinent at admission
| Definition: Report of incontinence by nurses on flow sheet in chart | | Only bivariate analyses were reported primarily xˆ2
| | | Urinary incontinence was associated with stroke p < .0003
| | | Fecal incontinence was associated with urinary incontinence p < .0001 (80%) and dysphagia p < .0001 (81%)
| | | Fecal incontinence was associated with functional impairment as measured by an AFIM score, p < .0001 of those with an AFIM score = >80, 1% had fecal incontinence
| | | If AFIM score 60–80, 17% had fecal incontinence
| | | If AFIM score 40–60, 66% had fecal incontinence
| | | If AFIM score <40, 94% had fecal incontinence
| | | Urinary incontinence on admission was associated with UTI p < .001 18% 50% of residents admitted with incontinence remained incontinent on discharge
Bharucha, 2005 ^241^ | 2800 of 5300 women (53%) responded to survey; sample included NH residents women were > 20 years old | Gender: All female | Prevalence of Incontinence
Cross-Sectional | Methods: Questionnaire to age stratified random sample of women in a Rochester epidemiology project | Subject Race: White | Age adjusted fecal incontinence prevalence in last year = 12.1% (I = 11.0 – 13.1)
Adjustment For: Results were adjusted by age and the 2000 US white female population on the US census | Definition: QA: "In the past 12 months have you experienced accidental leakage of solid or liquid stool? | Residency: Olmsted County, MN | Prevalence of any fecal incontinence history = 14% (I = 12.8 – 15.1)
| Fecal Incontinence severity score was calculated (max score = 13) using a summative scale: an MD assigned a severity score to selfreported fecal incontinence symptoms, no question was reported for any fecal incontinence history | | Fecal incontinence frequency m = 503
| Quality of Life: 15 domains with 4 levels 0 = none, 1 = mild, 2 = moderate, 3 = severe | | < 1 per month 55%, adjusted prevalence 6.7(5.8 – 7.5)
| Quality of Life: QAs were not tested for validity or reliability | | 1 per month 24%, adjusted prevalence 2.9(2.3–3.4)
| | | 1 per week 12%, adjusted prevalence 1.4(1.0–1.8)
| | | Several times a week 9%, .9(.6–1.2)
| | | Daily 2%, adjusted prevalence .2(.1–.3)
| | | Amount m = 502
| | | Small (stain underwear only) 60%, 7.3(6.5–8.2)
| | | Moderate (need to change underwear but not clothing) 33%, 3.8(3.2–4.4)
| | | Large (change outer clothing) 7%, 0.8(0.5–1.1)
| | | 23% of respondents reported fecal incontinence had moderate or severe impact on quality of life in > 1 domain; there was no significant difference in impact of fecal incontinence on specific quality of life domains.
Johannsson, 2002 ^242^ | 556 consecutive patients who had Milligan-Morgan hemorochoidectomy at 4 clinics in Sweden between 1987- 1995; 40 died, 9 lost to follow up so 507 received questionnaires - ok | Age: x = 51 years, range = 20–82 | Prevalence of Fecal Incontinence overall
| Methods: Questionnaire mailed | Gender: Male = 231 (55%), Female = 187 (45%) | 56 were incontinent of liquid feces
| Definition: Anal incontinence | Residency: Sweden | 11 were incontinent of solid feces
| | | 72 were incontinent of gas
| | | Note: pre-operative incontinence was not reported
| | | 25 patients who leaked liquid stool related it to the surgery
| | | 6 who leaked solid stool related it to surgery
Karasick, 1997 ^243^ | Cases of 354 consecutive female patients who had fluoroscopically guided defecograpy between March 1986 and March 1996 | Age: X(SD) = 57.7(16.3) years | Prevalence of Fecal Incontinence
Retrospective cross sectional | Methods: Chart review for fecal incontinence telephone interview for OB history and surgery | Gender: All female | 40% m = 108
| Definition: Fecal Incontinence = widened anal canal (> 2 cm) with barium leakage at rest | Residency: United States | No multivariate analysis of risks only correlations
Cavaliere, 1995 ^244^ | Records from Cleveland Clinic and Mayo clinic, 178 patients undergoing protocsigmoidscopy and manual colorectal anastomsis for rectal cancer 1981-1990 study n = 68 | Age: not reported | Incidence of Fecal Incontinence
Retrospective chart review | Methods: Questionnaire | Gender: not reported | 57% m = 18 had fecal incontinence
Adjustment For: Follow up was 50 months | Definition: Not reported | Residency: not reported | Note: Whether patients had fecal incontinence before surgery was not reported
| Residents > 65 years in 241 nursing homes or hospitals; (N = 6,079) number of acutely ill = 627 | | Prevalence of Incontinence
| | | Urinary incontinence = 27%
Peet, 1995 ^245^ | Methods: “Census” probably means “observation” | Age: x = 82.7 years, SD = 7.8 years | Fecal Incontinence = 1.8%
Cross Sectional | Definition: none reported | Residency: Leicester, UK | Urinary incontinence and fecal incontinence = 34.3%
| | | Note: I did not include those with a urinary catheter as having urinary incontinence
| | | Residents > 65 years in 241 nursing homes or hospitals
Fialkow, 2003 ^246^ | University of Washington Medical Center - Roosevelt Urology and Urogynecology Clinic; All new adult community patients to clinic between 6/13/2000 and 7/1/2002 were sent a questionnaire; ages 18–90 years | Age: x = 55.9, SD = 14.3 | Prevalence of Incontinence
Adjustment For: Exclusions | Methods: questionnaire, N = 7732 | Gender: all female | Fecal incontinence n = 18
| Definition: Wexner scale of fecal incontinence severity I-QOL for urinary incontinence QoL 3 day voiding diary for urinary incontinence | Subject Race: 80% white | Urinary incontinence m = 342
| Urinary incontinence severity was measured by questions on questionnaire on 5 point Likert scale 1 = mild, 5 = severe | Residency: United States | Double incontinence m = 65 mean (SD) Wexner Score for fecal incontinence = 12.33 (4.7)
| SF12 measured functional status | | Urinary incontinence severity score = 3.1(1.3) in those with UI
| | | I-QOL total score; urinary incontinence = 62.9, double incontinence = 46.4, p = < .001
| | | I-QOL avoid/limit score; urinary incontinence = 59.9, double incontinence = 43.8, p = < .001
| | | I-QOL psychosocial; urinary incontinence = 71.6, double incontinence = 53.2, p = < .001
| | | I-QOL embarrassment; urinary incontinence = 50.4, double incontinence = 37.9, p = < .001
| | | SF-12 PCS12 (physical); fecal incontinence = 45.5, urinary incontinence = 42.4, double incontinence = 38.6, p = .027
| | | SF12 MCS12 (mental); fecal incontinence = 46.9, urinary incontinence = 50.4, double incontinence = 46.4, p = .032
Bek, 1992 ^247^ | 152 women who had a complete obstetric tear of anal sphincter at 1 hospital and 121 responded, 56 had another vaginal delivery so study sample equals these - 56 | Age: not reported | Prevalence of Incontinence
| Methods: questionnaire by mail | Residency: Denmark | Fecal incontinence after tear
| Definition: anal incontinence included flatus but separated fecal soiling results for incidence but not for repression analysis, those results are not included | | N = 3 but fecal incontinence was only transient
| Note: incontinence before sphincter tear was not reported | | Fecal incontinence after next delivery m = 9
Goode, 2005 ^248^ | Medicare lists of 5 counties (3 rural, 2 urban) of west central Alabama; N = 1,000 community living people | Subject Race: Stratified as 25% black female, 25% black male, 25% white female, 25% white male | Prevalence of fecal incontinence
Cross Sectional | Methods: interview using a structured questionnaire | Residency: Alabama, U.S | Overall fecal incontinence = 12%
| Definition: Fecal incontinence = affirmative response to QA: “In the past year, have you had any loss of control of your bowels, even a small amount that stained the underwear?” Mild fecal incontinence = < 1 × 1 month | . | 12.4% = male
| Urinary incontinence definition was not reported | | 11.6% = female
| | | 11.2% = white male
| | | 13.5% = African American male
| | | 14% = white female
| | | 9.2% = African American female
| | | no significant difference
| | | 77.6% of women with fecal incontinence and urinary incontinence vs. 48% without fecal incontinence p = .001
| | | 50% of men with fecal incontinence had urinary incontinence vs. 34.9% without fecal incontinence p = .02
| | | Moderate /severe fecal incontinence in m = 5.8% and in F = 4.6% p = .40 and no difference by race p = .57
| | | In Women
| | | Chronic diarrhea OR = 4.55(2.03–10.20)
| | | Urinary incontinence OR = 2.65(1.34–5.25)
| | | Hysterectomy and oopharectomy 1.93(1.06–3.54)
| | | Poor self perceived health status 1.88(1.01–3.5)
| | | Comorbidity scale OR = 1.29(1.07–1.55)
| | | In Men
| | | Chronic diarrhea OR = 6.08(2.29–16.16)
| | | swelling in feet and legs OR = 3.49(1.8–6.76)
| | | TIA 3.11(1.3–7.41)
| | | Depression score > 5 OR = 2.83(1.27–6.28)
| | | Lives alone OR = 2.38(1.23–4.62)
| | | Prostate disease OR = 2.29(1.04–5.02)
| | | Poor self perceived health 2.18(1.13–4.20)
Bergmark, 2002 ^249^ | 332 women registered at 7 departments of gynecologiocal - oncology having early cervical cancer between November 1996 and May 1997; N = 256 responses (77%) | Age: ×(SD)age = 51(.77) | Impact of incontinence on life.
Cross Sectional | Methods: Questionnaire | Gender: all female | Women treated with surgery and external radiotherapy reported fecal leakage (distress).
| Definition: 6 category response distress about symptom was reported only | Residency: Sweden | Much distress = 14% (11/78)
| Distress about fecal leakage by women treated with surgery alone: much = 2% (2/93); moderate = 3% (3/93) | | Moderate distress = 19% (15/78)
| Distress after treatment with radical radiation alone: much = 10% (2/20); moderate = 15% (3/20)
Guren, 2005 ^250^ | Patients in Norwegian Rectal Cancer | Age: Median = 73, | Prevalence of Fecal Incontinence
Cross Sectional | Registry who had anterior resection for rectal cancer between 11/03 and 12/01; N = 319 respondents 80% | Range = 39–94 years | Incontinence of loose stools
| Methods: Mail questionnaire | Gender: Male = 179, | Anastomsis level ≤ 3 cm
| | Female = 140 | Never = 12
| | Residency: Norway | < 1 per week = 7
| | | 1–6 per week = 8
| | | Every day = 3
| | | Anastomosis level 4.6 cm
| | | Never = 51
| | | < 1 per week = 30
| | | 1–6 per week = 23
| | | Every day = 4
| | | Anastomosis level 7–8 cm
| | | Never = 28
| | | < 1 per week = 15
| | | 1–6 per week = 3
| | | p = .07
| | | Incontinence of solid stool
| | | Anastomosis level ≤ 3 cm
| | | Never = 19
| | | < 1 per week = 7
| | | 1–6 per week = 2
| | | Every day = 2
| | | Anastomosis level 4.6 cm
| | | Never = 87
| | | < 1 per week = 14
| | | 1–6 per week = 9
| | | Every day = 3
| | | Anastomosis level 7.8 cm
| | | Every day = 0
| | | p = .01
Gunther, 2003 ^251^ | All patients seen in clinic who under-went operation for familial adeno-matous polyposis between 1971 and 2000; N = 151 candidates data available for 59 patients | Age: IRA × age = 53 years; IPAA = 45 years | Incidence of Fecal Incontinence
Comparative, cohort, retrospective | Methods: Telephone interview | Gender: IRA: Male = 11, Female = 11; IPAA: Male = 22, Female = 15 | Wexner Score for incontinence for liquid stool IRA = .11, IPAA = .73
| Definition: Jorge-Wexner least-worst score (0–4 scale) and Jostarndt score (0–6 scale) | Residency: Germany | Wexner Scores for Incontinence of Solid Stool IRA = 0, IPAA = .38
| 2 surgeries compared: IRA (ileorectal anastomosis) N = 22: IPAA (ideal pouch anal anastomosis) N = 37 | | Jostarndt score for incontinence of liquid stool IRA = 5.84, IPAA = 5.05
| Note: No risks or quality of life could be reported because they used total Wexner and Jostarndt scores which include incontinence of gas | | Jostarndt score for incontinence of solid stool IRA = 6, IPAA = 5.68
Adolfsson, 1998 ^252^ | CA (prostate cancer) group: men aged 50–80 years diagnosed in 1992 with prostate cancer with prostate cancer in Stockhold region in CA and population. | Gender: All male | Prevalence of Incontinence
Cohort, comparison | Control Group: men in population registry in Stockholm randomly selected in a stratified fashion to have an age distribution similar to CA patients; mailings N = 431 men with CA, N = 435 men without CA | Residency: Sweden | Fecal leakage in men with prostate cancer: 8% (27/321); control men 4% (13/292)
Adjustment For: Analysis adjusted for age as a 3 category variable | Respondents: 342 men with CA (79%) and 314 controls (72%) | | Urinary leakage in men with prostate cancer: 30% (93/313); control men: 14% (42/291)
| Methods: Mail questionnaire | | Relative risk for fecal leakage: men with prostate cancer = 2.2(1.2–2.4); control men = 1.0
| Definition: Not defined specifically, 1 question of questionnaire | | Note: multiple variable analysis was not performed
Ellerkmann, 2001 ^253^ | 237 consecutive patients with symptomatic pelvic organ prolapse who were examined within a 24 month period | Age: x = 57.2 years, range 23–93 years | Prevalence of Incontinence
Descriptive | Methods: Questionnaire at clinic | Gender: all female | Urinary incontinence = 73% of whom 13% had stress urinary incontinence; 5% urge urinary incontinence, 76% double urinary incontinence
| Definition: Likert scale was used for incontinence severity, 0 = none, 3 = severely | | Fecal incontinence = 31%
| | | 46 women with fecal incontinence (63%) said fecal incontinence interfered with normal activities
Garcia-Aguilar, 1996 ^254^ | 864 patients with open (N = 521) vs. closed (N = 343) sphincterotomy were surveyed and 63.5% (N = 549) responded of whom 62/2% had open technique | Age: x = 44 years, open = 44 years, closed = 44.7 years | Incidence of Fecal Incontinence in “open” surgery: soiling of underclothing occurred in 26.7% vs. 16.1% of closed surgery (p < .05)
Cross Sectional | Methods: Questionnaire | Gender: of all patients females = 57% | Accidental bowel movement occurred in 11.8% of open surgery patients vs. 3.1% of closed (p < .05)
| Definition: soiling of underclothing and accidental bowel movement | Residency: United States
| Note: pre-op fecal incontinence rates were not reported
Amdur, 1990 ^255^ | 225 patients treated by external beam irradiation at the University of Florida between 1964 and 1982 for localized adenocarcinoma of the prostate | Age: no demographic information given | Incidence of fecal incontinence
Retrospective | Methods: Chart review | Gender: All male | Moderate fecal incontinence = 5 patients
| Definition: moderate = requiring a minor surgical procedure or significant medical management and/or producing minor disability severe = resulting in major surgical procedure or causing significant disability | | Severe fecal incontinence = 2 patients
| | | Note: baseline prevalence of fecal incontinence was not reported
Sobhgol, 2007 ^256^ | N = 319 women at 2 clinics aged 15–49 years, married, non-pregnant, non-breast feeding | Age: 15–49 years ×(SD) = 33.8(8.3) | Prevalence of Fecal Incontinence
Cross Sectional | Methods: Questionnaire by interview in clinic | Gender: All female | Fecal incontinence in women with dyspareunia (pain after intercourse) = 3/179 = 1.7%
| Definition: Not defined | Residency: Iran | Fecal incontinence in women without dyspareunia = 1/145 (0.7%)
Drossman, 1993 ^257^ | Purchased mailing list of consumer households in 48 US states; stratified probability random sample of 8250 households quotas of sampling were according to age, gender, income, household density and size was selected; 5430 respondents (66%) | Age: ×(SD) = 49(15.1) years | Prevalence of Fecal Incontinence
Cross Sectional | Methods: Mail survey | Gender: 51% female | Fecal soiling = 7.1%
| Definition: Results reported as fecal soiling and gross incontinence | Subject Race: Database lease represents white households
| | Residency: United States
Nicholls, 1990 ^258^ | 205 patients operated on during 1977 to 1987 for ulcerative colitis, familial adenomataus polyps or functional bowel disease; 3 pouches were constructed: S, J, W | Age: 33.5(12–16), ×(SD) years | Incidence of Fecal Incontinence
Cohort | Methods: Patient chart | Gender: 116 males, 89 females | Fecal leakage occurred in 2/174
| Definition: Not reported | Residency: London, England | Note: preoperative fecal incontinence was not reported
Crook, 1996 ^259^ | 202 prostate CA patients treated consecutively from 3/87–2/93 who had a minimum of 1 year follow up N = 192 95% response | Age: x = 70 years, range = 49–87 years | Prevalence of Fecal Incontinence
Cross Sectional | Methods: Mail questionnaire | Gender: All male | Prevalence of “Bowel incontinence”
| Definition: Fecal incontinence and urinary incontinence were not defined | Residency: Canada | 13–23 months after treatment = 8%
| | | 24–35 months after treatment = 8%
| | | 36–47 months after treatment = 8%
| | | 48–59 months after treatment = 9%
| | | Prevalence of Urinary incontinence daily
| | | 13–23 months after treatment = 14%
| | | 24–35 months after treatment = 19%
| | | 36–47 months after treatment = 18%
| | | 48–59 months after treatment = 16%
| | | ≥ 60 months 25%
| | | Prevalence of Urinary incontinence ≥ 1 Tbl
| | | 13–23 months = 9%
| | | 24–35 months = 7%
| | | 36–47 months = 8%
| | | 48–59 months = 8%
| | | ≥60 months 10%
Schwartz, 2002 ^260^ | Part of a case-control study o occupational risk factors and prostate cancer; letters were sent to 501 men in a population based cancer registry. (79.4%) 398 cancer patients and 181 controls were interviewed. Those with radical prostatectomy (RP) were compared to those with radiation treatment (RT). | Age: | CA group
Cross sectional, comparative | Convenience samples of controls from the parent study were invited to participate or some were randomly selected from Medicare recipients. | Gender: All male | Age 50–59
Time between end of treatment and interview was x = 286 days; range = 0–965 days. | | Residency: Wayne County, MI | RP = 39/130 (30%)
| | | RT = 13/115 (11.3%
| | | Controls = 47/181 (26%)
| | | Age 60–69
| | | RP = 80/130 (61.5%)
| | | RT = 46/115 (40%)
| | | Controls = 89/181 (19.2%)
| | | Age ≥ 70
| | | RP = 11/130 98.5%)
| | | RT = 56/115 (48.7%)
| | | Controls = 45/ 181 (24.8%)
| | | P value < .001
| | | Race - Black
| | | RP = 58 (44.6%)
| | | RT = 60 (52.2%)
| | | Controls = 72 (39.8%)
| | | Race - White
| | | RP = 69 (53.1%)
| | | RT = 52 (45.2%)
| | | Controls = 101 (55.8%)
| | | Race - Other
| | | RP = 3 (7.3%)
| | | RT = 3 (2.6%)
| | | Controls = 8 (4.4%)
| | | Stool Leakage at baseline and past treatment (%)
| | | Stool Leakage
| | | Baseline RP group = 1.5%
| | | Post treatment = 6.2% p = (.049)
| | | Baseline RT group = 2.6%
| | | Post treatment = 18.3% p = .001
| | | Any urinary incontinence
| | | Baseline RP group = 19.2%
| | | Post treatment = 53.8%
| | | Baseline RT group = 25.2%
| | | Post treatment = 37.7% p = .047
| | | Multivariate Results of Treatment type and Risk of Complication
| | | Bowel Incontinence (RT vs. RP)
| | | All
| | | Odds ratio = 3.61
| | | 95% CI = 1.54–8.47
| | | White
| | | Odds ratio = 4.88
| | | 95% CI = 1.19–19.96
| | | Black
| | | Odds ratio = 2.38
| | | 95% CI = .77–7.34
| | | Urinary Incontinence (RP vs. RT)
| | | All
| | | Odds ratio = 2.87
| | | 95% CI = 1.52–5.44
| | | White
| | | Odds ratio = 6.59
| | | 95% CI = 2.09–20.80
| | | Black
| | | Odds ratio = 2.38
| | | 95% CI = 1.00–5.67
Talley, 1992 ^214^ | Random sample of 500 persons who attended Mayo Clinic in 1987-1990. | Age: ≥65 years | Prevalence of fecal incontinence
Cross sectional | Stratified by age (equal numbers in 5 year age groups) and gender (equal numbers in each age groups) | N = 328 (66% response rate) | Fecal Incontinence >1 time/week = 3.7% (95% CI = 1.6–5.9)
Adjustment For: age and sex adjusted to population of whites in US in 1980 census. | Methods: Postal questionnaire | Subject Race: White only | Fecal incontinence >1 time/week or need to wear a pad = 7% (4.1–9.9)
| Definition: Fecal incontinence as stool leakage; clinically significant fecal incontinence as leakage >1 time/week or need to wear a pad. | Residency: Olmsted County, MN | Fecal Incontinence >1 time/week
| Note: even though fecal incontinence definition as >1 time per week results are reported as >1 time/week. | | Age adjusted fecal incontinence in females = 3.1(0.39–5.9)
| | | Age adjusted fecal incontinence in males = 4.5(1.3–7.7)
| | | Overall age and sex adjusted = 3.7(1.6–5.9)
| | | Wears a Pad.
Gurbuz, 2005 ^261^ | Methods: Questionnaire | Age: x = 42.48 years, | Age adjusted fecal incontinence in females = 6.7(2.9–10.6)
Cross sectional | Definition: Answer 1021 patients who were admitted to gym clinic of authors between 3/01 and 4/02 (N = 1021) agreed to complete questionnaire about urinary incontinence and fecal incontinence (92.6%). | SD = 10.6 years | Age adjusted fecal incontinence in males = 4.6(1.4–7.8)
| of yes to question: Do you currently have some involuntary loss of urine? | Gender: All female | Overall age and sex adjusted = 6.1(3.3–8.5)
| Fecal incontinence question: Do you accidentally lose stool from the rectum, occurring once a month or more frequently? | Residency: Turkey | M for fecal incontinence = 1017 patients overall fecal incontinence
| | | prevalence = 3.1% (N = 32); had enuresis in childhood?
| | | Fecal incontinence:
| | | Yes = 13(5.7%),No = 19(2.4%),Total = 32(3.1%)
| | | Urinary incontinence:
| | | Yes = 181(79%),No = 678(85.6%),Total = 85.9(84.1%)
| | | Stress urinary incontinence:
| | | Yes = 28(12.2%), No = 51(6.4%), Total = 79(7.8%)
| | | Urge urinary incontinence:
| | | Yes = 11(4.9%), No = 39(5%), Total = 50(4.9%)
| | | Mixed urinary incontinence:
| | | Yes = 9(3.9%), No = 24(3%), Total = 33(3.2%)
Hahnloser, 2004 ^262^ | Females <40 years at time of ideal pouch anastomosis for ulcerative colitis between 1981 and 1995 (N = 544), 83% response rate (450 responded), 135 had pregnancies | Gender: All female | Fecal Incontinence in those with ≥1 vaginal delivery vs. C section
Comparative | Methods: Mail questionnaire | Residency: Mayo clinic in Minnesota and Zurich hospital in Switzerland | No fecal incontinence
Adjustment For: Multivariate analyses did not compare groups | Definition: None reported | | Vaginal delivery = 76, C section = 85
| | | Occasional fecal incontinence
| | | Vaginal delivery = 20, C section = 13
| | | Frequent fecal incontinence
| | | Vaginal delivery = 4, C section = 2, p = .3
| | | Fecal incontinence during the day before pregnancy:
| | | None = 79, Occasional = 20, Frequent = 1
| | | Fecal Incontinence during the day first follow up after pregnancy:
| | | None = 77, Occasional = 21, Frequent = 1,
| | | Fecal incontinence during the day - most recent follow-up:
| | | None = 64, Occasional = 36, Frequent = 0, p = .01
| | | Fecal incontinence at night before pregnancy:
| | | None = 59, Occasional = 33, Frequent = 8
| | | Fecal incontinence at night - first follow up after pregnancy
| | | None = 52, Occasional = 39, Frequent = 9
| | | Fecal incontinence at night - most recent follow up
| | | None = 37
Dayton, 1996 ^263^ | Patients who underwent ideal pouch anal anastomosis between 1983 and early 1996; N = 355. | Age: <55 years = 423; | Occasional = 63
Cohort | Methods: Prospective collection of data then review of data registry. | >55 years = 32 | Frequent = 0
| Definition: Not defined | Residency: Utah, USA | p = .06
| | | Percent with Daytime Incontinence
| | | At 3 months, < 55 years
| | | Occasional = 6
| | | Often = 2
| | | Daily = 2
| | | Never = 90
| | | At 3 months, > 55 years
| | | Occasional = 26 **
| | | Often = 5
| | | Daily = 0
| | | Never = 68 **
| | | At 6 months, < 55 years
| | | Occasional = 4
| | | Often = 2
| | | Daily = 1
| | | Never = 93
| | | At 6 months, > 55 years
| | | Occasional = 10
| | | Often = 10 *
| | | Daily = 1
| | | Never = 93
| | | At 12 months, < 55 years
| | | Occasional = 4
| | | Often = 1
| | | Daily = 2
| | | Never = 93
| | | At 12 months, > 55 years
| | | Occasional = 6
| | | Often = 0
| | | Daily = 0
| | | Never = 94
| | | Percent with Night Incontinence
| | | At 3 months, < 55 years
| | | Occasional = 24
| | | Often = 6
| | | Daily = 3
| | | Never = 68
| | | At 3 months, > 55 years
| | | Occasional = 42
| | | Often = 21**
| | | Daily = 5
| | | Never = 32**
| | | At 6 months, < 55 years
| | | Occasional = 18
| | | Often = 8
| | | Daily = 4
| | | Never = 70
| | | At 6 months, > 55 years
| | | Occasional = 22
| | | Often = 33**
| | | Daily = 0
| | | Never = 44*
| | | At 12 months, < 55 years
| | | Occasional = 17
| | | Often = 4
| | | Daily = 5
| | | Never = 74
| | | At 12 months, > 55 years
| | | Occasional = 16
| | | Often = 15**
| | | Daily = 10
Cukier, 1997 ^264^ | Patients with a diagnosis of IBS or IDI (Idiopathic detrusor instability) during 1993-95 at 1 hospital; controls were recruited from the day surgery unit | Residency: UK | Never = 60
Cross Sectional and comparative | N(controls) = 55 responses | | * = p <.05
| N(IBS or IDI) = 49 responses | | ** = p <.01
| Methods: Mail questionnaire | | Incontinence of Solid Stool
| | | Male IBS = 0/23
| | | Female IBS = 3/41 (7%)
| | | Male IDI = 2/20 (10%)
| | | Female IDI = 5/25 (20%)
| | | Male controls = 0/23
| | | Female controls = .31
| | | Incontinence of Liquid Stool
| | | Male IBS = 0/23
| | | Female IBS = 1041 (24%)
| | | Male IDI = 6/20 (30%)
Lovatsis, 2002 ^265^ | 293 patients who had sacrospinus vault suspension at 1 hospital between 11/93 and 12/98 | Age: X = 61.7 years; | Female IDI = 6/25 (24%)
Retrospective chart review | Results report anal incontinence that includes flatus but a subgroup with fecal incontinence of solid stool | Range = 30–88 years | Male controls = 0/23
| | Gender: All female | Female controls = 0/31
| | Residency: Toronto, Canada | Severity of fecal and urinary incontinence
| | | 30 patients who had fecal incontinence of solid stool only before surgery reported a “cure” - no fecal incontinence after surgery
| | | An additional 4 who had fecal incontinence of solid stool only reported no change after surgery
Menter, 1997 ^266^ | Patients injured ≥20 years who received rehab at spinal center at 1 of 2 hospitals who participated in a study in both 1990 and 1993; m = 221. | Age: Tetraplegia, ABG(m = 65), age = 51 years | Prevalence of Fecal Incontinence
Cross Sectional | Methods: Questionnaire and chart review | Paraplegia, ABC = 56.3 years (m = 109) | Bowel accidents (FI)
| Definition: Fecal incontinence = bowel movement of any consistencyincluding diarrhea like stool- occurring without preparation or intent and not due to recent GI acute illness such as influenza or food poisoning and not attributable to recent food intake such as spicy foods, etc. | Tetraplegia or paraplegia grade D (n = 47), age = 56.6 years | Tetraplegics n = 19(29%)
| | Residency: UK | Paraplegics n = 30 (27.5%)
| | | All DS n = 11(23.4%)
| | | Total = 60/221 (27.1%)
Gupta, 2005 ^267^ | 1,000 patients with grade III or IV hemorrhoids treated with radio frequency ablation followed by plication. | Age: ×(SD) = 39.8, (13.6) years | Fecal incontinence = 0%
Retrospective | Methods: Chart review | Gender: 524 females
| | Residency: India
Malone, 1996 ^268^ | 144 patients with Spina bifida randomly selected from database of spina bifida association, 109 analyzed. | Age: x = 23.5 years | Prevalence of Incontinence
Cross sectional | Methods: Questionnaire by mail | range = 9–47.8 years | 55/104 (53%) regularly soiled (urinary or fecal incontinence)
| Definition: as ‘soiled’ which represented urinary incontinence or fecal incontinence, | Gender: 67 female | Fecal and urinary incontinence = 31 (30%)
| | 42 male | Fecal incontinence only = 24 (23%)
| | Residency: UK | Urinary incontinence only = 24 (23%)
| | | Moderate Soiling = 25 (45%)
| | | Severe Soiling = 18 (33%)
Helgason, 1996 ^269^ | 450 men in 1992 in Stockholm, 50–80 years who had diagnosis of prostate cancer and same number of men randomly selected from same geographic area. | Age: Prostate cancer x = 72 years | Prevalence of Incontinence
Cross sectional and comparative | N = 314 controls analyzed | Range = 51–80 | Fecal incontinence in prostate cancer men = 12/321 (4%)
| N = 342 prostate CA analyzed | Controls x = 68 years | Urinary incontinence in prostate cancer men = 45/313 (14%)
| Methods: Mail questionnaire | Range = 50–80 years | Fecal incontinence in control men = 6/292 (2%)
| Definition: Not defined | Gender: Men only | Urinary incontinence in controls = 10/291 (3%)
| | Residency: Sweden
Buchanan, 2002 ^270^ | 14,009 admission MDS records from 6/22/98 – 12/31/2001 in NY state | Age: ×(SD) age of MS Residents = 57.5 (13.9) years | Prevalence of Incontinence
Cross sectional and comparative | Definition: MDS items | All others = 76(15.3) years | Bowel continence in MS residents
| | Gender: MS residents = 70.3% female | Fecal incontinence = 39.1%
| | All other = 62.4% female | Frequent fecal incontinence = 7.5%
| | Residency: NY state | Occasional fecal incontinence = 5.5%
| | | Usual continence = 5.6%
| | | Continent = 42.3%
| | | Urinary incontinence in MS residents
| | | Urinary incontinence = 21.4%
| | | Frequent urinary incontinence = 9.3%
| | | Occasional urinary incontinence = 5.6%
| | | Usual continence = 4.8%
| | | Continence = 59%
| | | All others (non MS)
| | | Fecal incontinence = 22.5%
| | | Frequent incontinence = 6.8%
| | | Occasional incontinence = 5.2%
| | | Usual continence = 5.7%
| | | Continent = 59.8%
| | | Urinary incontinence = 19.1%
| | | Frequent incontinence = 11.9%
| | | Occasional incontinence = 7.7%
| | | Usual continence = 7.2%
| | | Continence = 54%
| | | White Non Hispanics: MS = 85.1%, All others = 81.2%
| | | Black: MS = 11.4%, All others = 11.4%
| | | Hispanic: MS = 2.3%, All others = 4.8%
| | | American Indian/Alaska native: MS = ≤11%, All others ≤11%
| | | Asian: MS ≤1%, All others = 1.9%
Zorzon, 1999 ^271^ | 108 patients with MS consecutively selected from a clinic, | Age and Gender: | Prevalence of Incontinence
| 97 patients with chronic disease (arthritis, lupus, ankylosing spondylitis) seen in rheumatic diseases center, | MS patients; | MS patients
| 110 healthy volunteers (health professionals and friends/relatives of patients and investigators). | 70 females; | Urinary incontinence = 31 (28.7%)
| Methods: Structured interview | ×(SD) age = 40.5 (11.2) years | Female = 18 (25.7%)
| Definition: no definition of fecal incontinence or urinary incontinence was reported | Chronic disease patients; | Male = 13 (34.2%)
| | 65 females = 41(11.9) years | Fecal Incontinence = 10 (9.3%)
| | Healthy controls; | Female = 9 (12.9%)
| | 71 females = 41.1 (12.6) years | Male = 1 (2.6%)
| | | Chronic Disease patients
| | | Urinary incontinence = 3 (3.1%)*
| | | Female = 2 (3.1%)*
| | | Male = 1(3.1%)**
| | | Fecal incontinence = 0**
| | | Healthy Controls
| | | Urinary incontinence = 2 (1.8%)*
| | | Female = 2 (2.8%)*
| | | Male = 0
| | | Fecal incontinence = 0*
| | | *p < .0001
| | | **p .01
Nelson, 1995 ^272^ | The population in Wisconsin sampled in the Wisconsin Family Health Survey, 6959 individuals and 2570 households responded. | Age: >65 years | Incidence of Fecal Incontinence
Cross sectional | Methods: Phone interview | Gender: 30% men | 153 were incontinent of stool or gas (anal incontinence) 36% of 153 were incontinent of solid stool; 54% of 153 were incontinent of liquid stool.
| Definition: “Have you or anyone in your household experienced unwanted, unexpected or embarrassing loss of control of bowels or gas?” although fecal incontinence was outcome, results are reported separately for stool and gas incontinence. | 63% female | Note: risk factors were reported for anal incontinence and are not included here.
Giebel, 1998 ^273^ | Sample size = 500: 275 consecutive patients from the emergency department, 62 hospital employees, 115 patients who had arthroscopies, and 48 relatives of the above groups. | Residency: Germany | Prevalence of fecal incontinence
Cross sectional | Methods: Questionnaire | | 35.1% had soiling of underwear, more frequent in men (p <.01) but % in men and women not reported
| | | 4.8% were unable to control solid stool
| | | 6.6% were unable to control pasty stool
| | | 6.7% were unable to control liquid stool
| | | Lack of control of pasty and liquid stool less common in women p <.05 and p <.01
Brandeis, 1994 ^274^ | Residents >60 years old admitted to national Healthcare Nursing homes during 1988 and 1989. | Age: mean 81 ± 8 years old 73% female | Prevalence of Incontinence
Fecal incontinence was measured cross-sectionally, this was a prospective cohort study of pressure ulcers | Sample = 4,232 people | | 48% of residents had fecal incontinence
| Definition of Incontinence: Fecal incontinence as accidental loss of feces greater than once per week. Urinary incontinence as accidental loss of urine greater than once per week. | | 57% had urinary incontinence at baseline
Longstreth, 1993 ^275^ | Members of a large health maintenance organization (HMO) having a routine health exam. | Age: Mean = 51.8 years | Prevalence of Fecal incontinence
| Response rate = 64.9%, 1,264 of 1,956 responded, fecal incontinence information was available on 1,195. | Gender: 54.3% female | Number of men with fecal incontinence = 159
| Methods: Questionnaire | Subject Race: White = 82.1% | Number of women with fecal incontinence = 154
| Definition: “Do you ever lose control of your bowels (including soiling your underwear)?” | Asian = 4.7%
| | Black = 4.5%
| | Other = 2.1%
| | Hispanic = 6.6%
| | Residency: California
Khullar, 1998 ^276^ | All women referred to a urodynamic clinic during a 4 month period; sample size = 465 | | 26% (N = 121/465) had fecal incontinence to liquid or solid stool on postal questionnaire
Cross sectional | Methods: Postal questionnaire and interview | | 15% (N = 71/456) had fecal incontinence to liquid or solid stool when asked on interview
| Definition: “Do you leak from the back passage?” liquid, solid, or flatus | | Note: fewer women admitted having fecal incontinence when asked vs. mail study
Edwards, 2001 ^277^ | Random sample of 1,000 people aged 65 and older from each of 3 | Age: 58% were 65–74 years and 42% were ≥75 years | Prevalence of Incontinence
Cross sectional | Family Health Service registers; sample = 2,818 | Gender: 61% female | 2% of those 65–74 years old had fecal incontinence
| Methods: Interview | Residency: England and Wales | 3% of those ≥75 years had fecal incontinence
| Definition: Fecal incontinence as “Do you have any difficulty controlling your bowels?” | | 1% of men and 4% of women had fecal incontinence (p <.0005).
| Urinary incontinence as “Do you ever wet yourself if you are unable to get to the lavatory as soon as you need to, or when you are asleep at night, or when you cough or sneeze?” | | 18% had urinary incontinence.
| | | 1% of 1,099 men and 2.5% of 1,695 women had fecal and urinary incontinence.
| | | 69% of those who had fecal incontinence also had urinary and 17% of those without fecal incontinence had urinary incontinence (p <.000001)
| | | Note: only bivariate analyses were done and no multivariate analyses.
Lynch, 2001 ^278^ | 1,500 adults randomly selected from the electoral roll; response rate = 48%, 717 respondents. | Age: Median = 46 years, | Prevalence of Fecal Incontinence
Cross sectional | Methods: Postal questionnaire | Range = 18–70 | Fecal incontinence of solid stool was in 70(9.8%)
| | Gender: 388 males | Fecal incontinence of liquid stool was in 91(12.7%)
| | 329 females
| | Residency: New Zealand
Perry, 2002 ^279^ | 15,904 people aged 40 or more randomly selected from households in patient registry of the health authority. 10,116 surveys were analyzed | Age: Range = 40–80+ | Prevalence of monthly or more leakage was 3.3% and soiling was 2.7%
Cross sectional | Methods: Postal questionnaire | Gender: 54% female | Men soiling underwear = 9.6% vs. women = 7.5%
| Definition: Major fecal incontinence = soiling of underwear, outer clothing, furnishing or bedding several times per month or more | Subject Race: White = 93.2% | Prevalence of major fecal incontinence = 1.4%
| Minor fecal incontinence = staining of underwear several times a month or more | South Asian = 5.7%, | Prevalence of minor fecal incontinence = 1.7%
| | Other = 1.1% | A lot of impact on life
| | Residency: UK | Major fecal incontinence = 51.7%
| | | Minor fecal incontinence = 16%
| | | None or a little impact
| | | Major fecal incontinence = 48.3%
| | | Minor fecal incontinence = 84%
Okonkwo, 2002 ^280^ | Patients who presented to the gynecology clinic (N = 3963) in 3 states in Nigeria and whose symptoms were not related to pelvic organ prolapse. | Age: Range = 20–50+ years | Prevalence of fecal incontinence of liquid stool = 2.67% and for solid stool = 2.17%
Cross sectional | Methods: Structured questionnaire | Gender: All female | Parity had no relation to fecal incontinence in bivariate analyses
| | Residency: Nigeria
Henningsohn, 2002 ^281^ | Patients who had urinary bladder cancer treated with radical radio therapy before 1995 (N = 58); patients with radical cystectomy and urostomy (N = 251; and people randomly selected from general population (N = 310) as controls. | Age and Gender: age of radio therapy group (mean ± standard error of mean) at follow up | “Fecal leakage at least every month”
Cross sectional | Methods: Questionnaire | Male = 78.1 ± 0.8, | Radiotherapy group prevalence = 8/48 (17%)
| Definition: Fecal incontinence as fecal leakage at least every month. | Female = 80.5 ± 1.2 | Cystectomy group = 16/169 (10%)
| | Cystectomy: | Controls = 4/256 (2%)
| | Male = 73.6 + 0.5
| | Female = 76 + 0.7
| | Controls:
| | Male = 75.6 ± 0.4
| | Female = 76.8 ± 0.6
Sakakibara, 2001 ^282^ | 115 consecutive patients with Parkinson's disease seen at neurology clinic controls were 391 locals undergoing an annual health survey | Age: controls = 30–69 years, Parkinson patients age = 35–69 years | Prevalence of Incontinence
| Methods: Questionnaire | Gender: controls = 271 males and 120 females, Parkinson patients gender = 52 men and 63 females | Parkinson Patients
| Definition: “Do you leak feces?” | Residency: Japan | Fecal incontinence prevalence = ~6% in females and ~10% in males
| | | Stress urinary incontinence = ~38% in females and ~2% in males
| | | Urge urinary incontinence = ~26% in females and 30% in males
| | | Controls
| | | Prevalence of fecal incontinence = 0% in females and 4% in males
| | | Stress urinary incontinence = 30% in females and 2% in males
| | | Urge urinary incontinence = 6% in females and ~5% in males
| | | Note: findings are in bar graphs without values
Eason, 2002 ^283^ | Pregnant women who gave birth in 5 hospitals in 1995-1996 in Quebec Women were part of another study about perineal massage. | Sample size = 949 women | Incidence of Incontinence
Cross sectional | Methods: Mail questionnaire 3 months after delivery, 1,198 received a questionnaire. | | Fecal incontinence occurred in 3.1% overall
| | | Fecal incontinence occurred at least once daily in 0.3%
| | | Fecal incontinence was present in 1.8% who had a C section and 2.9% of those with vaginal delivery
| | | Note: multivariate analysis for fecal incontinence was not done due to small number affected
Teunissen, 2004 ^119^ | Patients >60 years old in 9 general practices from Jan. 1999–Aug. 2001 | Age: ≥60 years or over | Prevalence of Incontinence
Cross sectional | Methods: Questionnaire | Gender: Female = 3,159 | Fecal incontinence of solid stool = 36%
| Definition: Urinary incontinence = involuntary loss of urine twice or more per month | Male = 5,748 | Liquid stool = 19%
| Fecal Incontinence = involuntary loss of feces twice or more per month Double Incontinence = Urinary incontinence + fecal incontinence twice or more per month. | Residency: Netherlands | Mucoid stool = 45%
| | | Overall fecal incontinence = 6%
| | | Solid Stool Fecal Incontinence
| | | Men = 30% N = 41
| | | Women = 42% N = 52
| | | Liquid Stool Fecal Incontinence
| | | Men = 10% N = 13
| | | Women = 29% N = 37
| | | Mucoid Fecal Incontinence
| | | Men = 60% N = 80
| | | Women = 29% N = 37
| | | Overall Urinary Incontinence = 19%
| | | Overall Double Incontinence = 3%
Chen, 2003 ^284^ | Taiwanese women in a community in August 1999–March 2001, sample size = 1,247 | Age: mean = 43.2 years, SD = 15.1 | Prevalence of fecal incontinence = 2.8%
| Methods: Door to door survey and interview | Gender: All female | Prevalence of flatus = 8.6%
| Definition: Fecal incontinence = flatus incontinence and anal incontinence | Subject Race: All Asian Subject | Impact on life = 8.6% had fecal incontinence considered troublesome to their daily lives (N = 30 of 35)
| | Residency: Taiwan | Note: risk factors were only reported for anal incontinence
Goldberg, 2003 ^285^ | Mothers of multiples attending the National Organization of Twins Clubs in 2001, Sample size = 733 | Age: median = 37, range = 22–75 years | Fecal Incontinence in women with a C-section only = 5.8%
Cross sectional | Methods: Survey | Subject Race: 94% white | Fecal incontinence in previous vaginal delivery = 11%
| Definition: Fecal incontinence or flatal incontinence | 2.3% African American | In multivariate analysis, age was the only significant correlate; fecal incontinence increased by a factor of 2 per 10 years, p = .0001
| | 0.6% Asian American, | Overall fecal incontinence = 10%
| | 1% Hispanic | Fecal incontinence of liquid stool only = 5.9%
| | Residency: United States | Fecal incontinence of solid and liquid stool = 1.6%
Chiarelli, 2003 ^286^ | 586 women who had an instrumental delivery and/or delivered an infant 4000g or more at teaching hospitals, 913 women were approached | Age: 15–44 years | Fecal Incontinence Prevalence = 6.9%
Cross sectional | Methods: Survey | Gender: All female | 2.6% had solid stool fecal incontinence and 4.9% had liquid stool fecal incontinence
| Definition: Fecal incontinence (solid and/or liquid stool) at 12 months post partum | Residency: Australia | Risks for fecal incontinence at 12 months postpartum
| | | Urinary incontinence at 12 months post partum
| | | OR = 6.03
| | | CI = 2.37–15.33
| | | Constipation
| | | OR = 2.46 (1.11–5.46)
| | | Joint hypermobility
| | | OR = 2.75 (1.05–7.19)
Fenner, 2003 ^287^ | Primiparous women who delivered vaginally at a University Medical Center from 1/1/97 to 3/30/00; 2,941 were mailed and 943 completed the urinary questionnaire and 831 completed the bowel questionnaire | Age: mean = 27.34 years | Incidence of urinary incontinence overall
Cross sectional, retrospective | Methods: Mail questionnaire about urinary incontinence and fecal incontinence; charts were reviewed for anal sphincter tears | Gender: All female | 0.42% had a worse major problem of urinary incontinence bladder control
| Definition: Questions about urinary incontinence “I wet myself”, "I may have an accident:, “I may leak urine in them” | Residency: United States | 5.41% had a worse occasional inconvenience of urinary incontinence bladder control
| Note: I did not include results about fecal incontinence because there was no definition of fecal incontinence like for Urinary incontinence; findings were too vague describing “bowel function” or “bowel control” | | 21.74% had worse minor inconvenience
| | | 16.2% had urge urinary incontinence alone
| | | 14.6% had mixed stress and urge urinary incontinence
Korman, 2004 ^288^ | 150 consecutive patients who underwent radical retro-pubic (RRP) or radical perineal prostatectomy (RPP) and 75 age-matched controls who were biopsied; response rate was 89% N = 201 | Age: Age (years) and range | Prevalence of Fecal Incontinence
| Methods: Questionnaire- the bowel function domain of the Expanded Prostate Cancer Index composite Definition: uncontrolled leakage of stool or feces | RPP group = 61 (42–44) | RPP group = 5.4% (4/75)
| | RRP group = 63 (32–35) | RRP group = 6.4% (4/63)
| | Controls = 61 (35–39) | Controls = 4.8% (3/61)
| | Residency: United States | No significant difference
Delaney, 2003 ^289^ | 1,895 patients who had ileal pouch anal anastomosis (IPAA) and were followed for > 6 months | Age: <45 years = 1,410/ and 766 male | Bowel movement/night (1 year)
Cohort | Methods: Questionnaire | 46–55 years = 289/ and 174 male | <45 = 1.4
| Note: This study did not report fecal incontinence per se, they report never incontinence and seepage at night. | 56–65 years = 154/ and 100 male | 46–55 = 1.8
| | >65 years = 42/ and 31 male | 56–65 = 2.1
| | | >65 = 1.9
| | | Total = 1.5
| | | P <0.001
| | | Multivariable = 0.001
| | | Never Incontinent (1 year)
| | | <45 = 78
| | | 46–55 = 68
| | | 56–65 = 54
| | | >65 = 44
| | | Total = 73
| | | P <0.001
| | | Multivariable ≤0.001 (3 year)
| | | <45 = 74
| | | 46–55 = 66
| | | 56–65 = 49
| | | >65 = 36
| | | Total = 69
| | | P <0.001
| | | Multivariable ≤0.001 (5 year)
| | | <45 = 69
| | | 46–55 = 52
| | | 56–65 = 48
| | | >65 = 20
| | | Total = 64
| | | P <0.001
| | | Multivariable ≤0.001
| | | Seepage at night (1 year)
| | | <45 = 34
| | | 46–55 = 44
| | | 56–65 = 50
| | | >65 = 44
| | | Total = 38
| | | p = 0.001
| | | Multivariable = 0.001 (3 year)
| | | <45 = 31
| | | 46–55 = 37
| | | 56–65 = 46
| | | >65 = 58
| | | Total = 34
| | | p = 0.006
| | | (5 year )
| | | <45 = 35
| | | 46–55 = 39
| | | 56–55 = 48
| | | >65 = 64
| | | Total = 47
| | | p = .22
| | | Multivariable = .013
Lunniss, 2004 ^290^ | Patients referred to a tertiary center for physiological assessment of fecal incontinence between January 1995 and June 2002; sample size = 629 | Age: | Prevalence of passive fecal incontinence = 27% (N = 168)
Retrospective cohort analysis. | Methods: medical history and anorectal physiological assessment. | Median age = 53 years, range of 15–88 years (457 females) | Urge fecal incontinence = 27% (N = 170)
| Definitions of Incontinence: | Median age: 53 years | Post defecation fecal incontinence = 7% (N = 43)
| Passive fecal incontinence = fecal incontinence without patient's knowledge. | Range of 14–92 years (154 males)
| Post defecation fecal incontinence = fecal incontinence related to defecation.
| Wage fecal incontinence = fecal incontinence with awareness.
Chou, 2000 ^904^ | Women who had surgery for pelvic organ prolapse and/or urinary incontinence between June 1996 and February 1996 by 4 OB-gynecologists enterocele group (E) = 77 NOE = 233 patients | Age: E = 67 median, range (31–90 years), No E = 59(28–83) | Prevalence of Fecal Incontinence
Cross Sectional and comparative | Methods: Questionnaire | Gender: All female | in E = 12/72 (17%)
| Definition: Unreported | | no E = 31/215
| | | Note: not all not E answered question

Table F1e Prevalence of combined urinary and fecal incontinence in adults

Author, Year, Design, Adjustment for Confounding Factors | Subject Selection, Data Source, Methods to Measure Incontinence (survey, screening, case finding), Definition of incontinence | Prevalence (%) or Incidence of Combined Incontinence, Overall: by Type, Severity, and Impact on Life
Thomas, 2001 ^291^ | Canadian study of Health and Aging data set of 1990 of elderly > 65 years old, N=2,923 community living and institutionalized residents, 1, 255 = institutionalized | Stool Incontinence Adjusted Prevalence.
Cross sectional. | Method of Measurement: Survey. | No overall % was reported
Adjustment for age, sex, cognitive function, alcohol abuse, diabetes, stroke, hypertension, cardiac SUS, respiratory problems, cancers, history of falling, current depression, hearing or visual impairments. | Definition of incontinence: stool incontinence, urine incontinence. | No dementia = 1.78 (.97–2.59)
Age: >65 years | | Cognitive impairment but no dementia = 4.60 (3.25–5.95)
N = 4,178 | | Cognitive impairment with dementia = 31.9 (28.87–34.93)
| | Urine Incontinence Adjusted Prevalence
| | No dementia = 13.34 (11.27–15.41)
| | Cognitive impairment without dementia = 22.68 (199.99–25.37
| | Cognitive impairment with dementia = 49.29 (46.05–52.53)
MacArthur, 1997 ^292^ | All women who delivered a baby between April and September, 1992 at a maternity hospital in Birmingham, United Kingdom, who had some adverse post partum symptoms were interviewed about fecal incontinence. | Fecal Incontinence
Cross sectional | Data Source: Interview for fecal incontinence took place a mean of 45 weeks after birth. | Prevalence (present before child birth = 6.1%)
Age: not reported | Definition of Incontinence: Frank incontinence- “no warning that she needed to go” Soiling or staining on underwear, Urgency = felt the need to go but could not hold on. | Incidence (after childbirth) = 4% or 36
N = 760 | | Total n = 36
100% female | | Soiling = 36%
| | Frank Incontinence = 19%
| | Daily Symptoms not defined by type = 39%
| | Symptoms on some days of the week = 36%
| | 22% said fecal incontinence affected their life style
| | Soiling only = 8%
| | Frank incontinence only = 3%
| | Urgency only = 53%
| | Soiling and urgency = 19%
| | Frank incontinence and urgency = 8%
| | All 3 = 8%
Point prevalence study of patients with clinical MS attending a clinic for management of symptomatic bowl dysfunction in the United Kingdom. | Method of Measurement: Interview using a questionnaire | Fecal Incontinence
Age range: 28–73 years | Definition of FI: Current fecal incontinence = involuntary passage of stool at least once during preceding 3 months, Previous fecal incontinence = same definition except that occurred at least once more than 3 months previously | Current = 16/77
(Mean = 47 years) | | Previous = 23/77
N = 77 | | Current and Urgency urinary incontinence = 16/77
61% female | | Previous and urgency urinary incontinence = 23/77
Buchanan, 2002 ^293^ | Residents in hospice care, N = 40,622 | Bowel Incontinence;
Cross section of residents in hospice care in the U.S. | Method of Measurement: MDS admission records | Continent = 43.6%
Average age: 76.4 (SD 13.9) | Definition of Incontinence: MDS items for continence-bowel, continence-bladder | Usually continent = 5.7%
59% female | | Occasionally incontinent = 5.7%
85% white, 10% black, 1.1% | | Frequently incontinent = 7.4%
American Indian, <1% Asian, 3% Hispani | | Incontinent = 37.6%
| | Bladder Incontinence
| | Continent = 54.4%
| | Usually continent = 5.9%
| | Occasionally incontinent = 6.3%
| | Frequently incontinent = 9.4%
| | Incontinent = 24%
Buchanan, 2001 ^294^ | Method of Measurement: MDS | Bowel Incontinence
Cross sectional study of nursing home residents with MS at time of their admission from 6/22/98 – 1/17/2000 in U.S. (in New York from 1/11/98 – 1/17/2000). | Definition of Incontinence: MDS item for continence - bowel, MDS item for continence - bladder | Occasionally incontinent = 5.4%
Age: 57.98 (SD = 14.19) years | | Frequently incontinent = 7.3%
N = 9,013 | | Incontinent = 38.8%
70.2% female, | | Continent = 42.7%
White = 84.7%, Black = 11.2% | | Usually continent = 5.8%
American Indian/Alaska native, Asian ≤1%, Hispanic = 2.4% | | Bladder Incontinence
| | Occasionally incontinent = 5.6%
| | Frequently incontinent = 9%
| | Incontinent = 21.3%
| | Continent = 58.9%
| | Usually continent = 5.2%
Ostlbye, 2004 ^28^ | Method of Measurement: Survey | Prevalence of Fecal and Urinary Incontinence
Cohort of Canadian community living elderly (>65 years) in 1991-92; (over sampled very old 75–84 years 1.5 times; > 85 years 2 times m = 8,949) | Definition of Incontinence: Questions and answers from the survey, Urinary Incontinence = "Do you ever lose control of your bladder? "Fecal Incontinence = "Do you ever lose control of your bowels? "Double Incontinence = urinary incontinence and fecal incontinence, prevalence determined at survey wave 1, survey wave 2 was in 1996 and wave 3 was in 2001 | Overall urinary incontinence = 9% n = 314
Age: 77.3 years (mean for females) | Survey questions and answers risk factors or correlations | Overall fecal incontinence = 3% N = 119
75.3 years (mean for males) | Cognitive status by modified mini mental exam 3MS? | Prevalence by age and sex
Total N (female) = 5,322 | Medical conditions- stroke or effects of stroke, arthritis or rheumatism, kidney trouble, diabetes, trouble with feet or ankles | Urinary incontinence
| Lifestyle- “Do you engage in regular exercise?” Have you been a regular coffee drinker (every day)? Have you smoked cigarettes regularly (nearly every day)? On average, how many packs per day?" | 65–69 years 14.2% - 167/1177 of females, 6.3% - 64/1020 of males
| Cognitive Status: normal, moderately, or severely impaired | 70–74 years 15.9% - 156/982 of females, 7.2% - 54/752 of males
| Lifestyle - yes/no | 75–79 years 19.7% - 285/1446 of females, 9% - 88/950 of males
| Number of packs smoked- <1 per day, 1 per day, > 1 per day | 80–84 years 25% - 202/808 of females, 11.2% - 53/475 of males
| | 85–89 years 24.6% - 180/733 of females, 16.6% - 55/332 of males
| | 90+ years 29% - 51/176 of females, 16.9% -11/65 of males
| | Fecal Incontinence in Females
| | 65–69 years - 3.3% of females, 1.8% of males
| | 70–74 years - 3.8% of females, 2.1% of males
| | 75–79 years - 5.1% of females, 5.2% of males
| | 80–84 years - 6.8% of females, 5.3% of males
| | 85–89 years - 9.6% of females, 6.9% of males
| | 90+ years - 8.5% of females, 10.8% of males
| | Double Incontinence
| | 65–69 years - 1.0% of females, 0.6% of males
| | 70–74 years - 1.1% of females, 0.5% of males
| | 75–79 years - 2.4% of females, 1.3% of males
| | 80–84 years - 2.2% of females, 1.7% of males
| | 85–89 years - 4.2% of females, 3.6% of males
| | 90+ years - 3.4% of females, 4.6 % of males
| | Cumulative incidence was reported = persons continent at baseline who were incontinent both in wave 2 and 3 and in 1 follow up wave (2 or 3)
| | Overall cumulative incidence
| | Wave 2- urinary incontinence = 33% n = 76/741, fecal incontinence = 13% n = 11/757
| | Wave 3- New urinary incontinence = 22% n = 16/1170, remained urinary incontinence from wave 2 = 29% (n = 16), new fecal incontinence = 13% n = 4/1189, remained fecal incontinence from wave 2 = 14% n = 1
| | Wave 3- Urinary incontinence in wave 2 decreased in wave 3 = 49% n = 27/1170, fecal incontinence in wave 2 decreased in wave 3 = 72% m = 5
| | Urinary Incontinence
| | Female- 65–74 years = 14.3% (wave 2), 18.3% (wave 3); 75–84 years = 20.5% (wave 2), 20% (wave 3); 85+ years = 24.3% (wave 2), 34.4% (wave 3)
| | Male- 65–74 years = 8.6% (wave 2), 13.3% (wave 3); 75–84 years = 12.3% (wave 2), 18.3% (wave 3); 85+ years = 23.2% (wave 2), 13.2% (wave 3)
| | Fecal Incontinence
| | Female- 65–74 years = 5.3% (wave 2), 7% (wave 3); 75–84 years = 7.2% (wave 2), 11.1% (wave 3); 85+ years = 13% (wave 2), 15.3% (wave 3)
| | Male- 65–74 years = 4.1% (wave 2), 5.3% (wave 3); 75–84 years = 5.5% (wave 2), 9.7% (wave 3); 85+ years = 13.2% (wave 2), 20% (wave 3)
| | Double Incontinence
| | Female- 65–74 years = 4.2% (wave 2), 4.1% (wave 3); 75–84 years = 6.5% (wave 2), 8.6% (wave 3); 85+ years = 14.9% (wave 2), 13.9% (wave 3)
| | Male- 65–74 years = 2.8% (wave 2), 2.8% (wave 3); 75–84 years = 4.3% (wave 2), 5.2% (wave 3), 85+ years = 11.8% (wave 2), 5.6% (wave 3)
| | Significant Correlates
| | Female Urinary Incontinence
| | 3 children or = 1.75, ci = 1.29, 2.38
| | 2 children 1.52(1.13, 2.03)
| | age 75–84 = 1.47(1.2, 1.79)
| | 85+ years 1.78(1.35, 2.37)
| | smoke > 1 pack per day 1.41 (1.06, 1.87)
| | Coffee drinker 1.23(1.01, 1.51)
| | Medical
| | Stroke 1.61(1.07, 2.43)
| | Arthritis 1.32(1.08, 1.61)
| | Kidney 3.36(2.69, 4.21)
| | Correlates of Fecal Incontinence in Females
| | 75–84 years 1.55(1.06, 2.26)
| | 85+ years 1.91(1.14, 3.17)
| | Foot and ankle trouble 2.01(1.18, 3.44)
| | Correlates of Urinary Incontinence in Males
| | 85+ years 2.46(1.5, 4.02)
| | Diabetes 1.72(1.10, 2.66)
| | Kidney problems 4.29(2.99, 6.16)
| | Risks for Cumulative Incidence Reported
| | For Urinary Incontinence in Women
| | Stroke 1.58(1.13, 2.22)
| | Kidney Problems 1.69(1.22, 2.33)
| | Foot and ankle trouble 1.36(1.04, 1.78)
| | Fecal Incontinence in Women-Risks for cumulative incidence
| | Cognitive status 50 < 3MS < 78 1.80(1.02, 3.20)
| | Stroke 2.07(1.44, 2.98)
| | Cumulative Incidence Risks of Urinary Incontinence in Males
| | 75–84 years 2.97(1.64, 5.39)
| | 85+ years 3.41(1.44, 8.11)
| | Smoke > 1 pack per day 2.03(1.05, 3.9)
| | Diabetes 2.49(1.32, 4.69)
| | Foot or ankle trouble 2.01(1.18, 3.44)
| | Risks of Fecal Incontinence in Males
| | 85+ years 2.51(1.26, 5.01)
Chiang, 2000 ^295^ | Method of Measurement: Chart abstractions and MDS data were used. | Prevalence
Retrospective chart review, cross sectional design. | Definition of Incontinence: Double incontinence included residents with indwelling urinary catheters; no other definitions of incontinence were given. | Urinary incontinence only = 13%
Multivariate regression models controlled for patient characteristics of age, gender, Medicaid insurance status, and chronic disease conditions of CHF, emphysema, diabetes of stay in nursing home in U.S. | Fecal incontinence only group was dropped from analysis due to small Number | Fecal incontinence only = 6%
Separate models compared double incontinence residents with urinary incontinence only residents and continent (group C) residents. | Double incontinence group: x = 84 years; 77% female | Double incontinence = 54%
Average age: = 84 | Urinary Incontinence only group: x age = 83 years; 77% female C group: x age = 85 years; 72% female | Continent = 27%
N = 413 | Urinary incontinence only = 53, Fecal incontinence only = 9, fecal incontinence and urinary incontinence = 237, no incontinence = 114 = C group, residents were in 20 nursing homes in 3 states who were in another study about primary care | p < .05 on pair wise comparisons
| | Cognitive impairment
| | Double incontinence = 90%, C = 59%, urinary incontinence = 62%
| | Alzheimer's Disease
| | Double incontinence = 25%, C = 13%, urinary incontinence = 9%
| | Dementia diagnosis
| | Double incontinence = 46%, C = 22%, urinary incontinence = 17%
| | Impairment in transfer
| | Double incontinence = 94%, C = 54%, urinary incontinence = 77%
| | Locomotion impairment
| | Double incontinence = 86%, C = 54%, urinary incontinence = 68%
| | Bed Mobility impairment
| | Double incontinence = 80%, C = 33%, urinary incontinence = 47%
| | Stroke
| | Double Incontinence = 33%, C = 18%
| | Emphysema
| | Double incontinence = 5%, C = 19%, urinary incontinence = 19%
| | Adjusted regression values are reported here with population mean value and SD
| | Number of hospital stays per year: ×(SD) = 1.11(4.4)
| | Double incontinence = 2.92
| | Urinary incontinence = 9.74
| | C = 2.10
| | Number of emergency room visits per year: ×(SD) = .26(.81)
| | Double incontinence = .66, urinary incontinence = 1.34, C = .74
| | Beta Values
| | Number of hospital stays per year
| | Double incontinence vs. C = .07
| | Double incontinence vs. urinary incontinence = -.19
| | Number of Emergency room visits per year
| | Double incontinence vs. C = .04
| | Double incontinence vs. urinary incontinence = -.10
Chiai, 1995 ^296^ | Method of Measurement: data about fecal incontinence was obtained using a questionnaire. | Prevalence of fecal incontinence.
Cross section of consecutive patients with clinically significant MS attending national hospital in London, UK for management of bladder dysfunction. | Definition of Incontinence: Current fecal incontinence as involuntary passage of stool at least once in preceding 3 months. Previous fecal incontinence as involuntary passage of stool at least once more than 3 months previously. | Current fecal incontinence only; n = 12.
Age: 28–73 (average 47 years) | | Previous fecal incontinence only; n = 12.
N = 77 | | Constipation and current fecal incontinence; n = 4.
61% female (n = 47) | | Constipation and previous fecal incontinence; n = 11.
| | Normal bowel function; n = 25.
| | Constipation only; n = 13.
| | Note: all have “bladder dysfunction” also but this wasn't defined.

Table F1f Risk factors of fecal incontinence in adults

Author | Subject Selection, Data Source, Methods to Measure Incontinence (survey, screening, case finding), Definition of Incontinence. Definition of Risk Factors. | Level of Risk Factors | Prevalence (%) or Incidence of Fecal Incontinence, Overall: by Type, Severity, and Impact on Life
Sample
Abramowitz, 2000 ^297^ | Consecutive females 6 weeks before and 8 weeks after delivery. | Sphincter defects by endoanal ultrasound | Incidence of Incontinence of Liquid Stools After Delivery
Prospective, descriptive, observational study in France. | Exclusion criteria: No history of ano-rectal disease. Neurologic disease, or diabetes | | Primiparous = 0.9%
N = 259 | Method of Measurement: Questionnaire | | Secundiparous = 1.7%
100% female | Definition of incontinence: fecal incontinence = incontinence of flatus and liquid or solid stools | | Multiparous = 2.1%
No age given | | | Total incontinence of liquid stools = 1.4%
| | | Sphincter defects by endoanal ultrasound
| | | Various conditions of childbirth but although risk factors were assessed, they were for “anal incontinence” and not just leakage of stools
Zetterstrom, 1999 ^298^ | Of 345 primiparous women, 278 responded to questions about fecal incontinence, 38 had sphincter tears, 240 had non-sphincter tears. | Maternal age. Continuous duration of labor >12 hours (yes/no), 2nd stage of labor >1 hour (yes/no), use of oxytocin (yes/no), fundal pressure to assist delivery (yes/no), instrumental vaginal delivery (yes/no), sphincter tear (yes/no), lithotomy position (yes/no) | Prevalence of Fecal
Cohort study in Sweden. | Questionnaires 1 day, 5 months, and 9 months after delivery. | Fecal incontinence at 5 months risk factors per multivariate analysis. | Incontinence Before Pregnancy
100% female. | | Maternal age 2.7(1.2, 6.0). | Fecal incontinence = 2(1%) total
Age: X (SD) = 30 (4.1) years | | 2nd stage of labor >1 hour 2.2(1.1, 4.2) | 1(3%) those with a sphincter tear
| | Instrumental delivery 3.1(1.3, 7.4), Sphincter tear 3.0(1.3, 6.7) | 18(8%) those with no sphincter tears
| | Factor in Univariate Analysis. | No fecal incontinence = 92%, fecal incontinence < once per week = 1%, fecal incontinence > once per week = 0
| | Maternal age at 5 months 3.4(1.6, 7.1), at 9 months 3.1(1.5, 6.6). | Prevalence of Fecal Incontinence at 5 months after delivery
| | Labor > 12 hours at 5 months 2.6(1.4, 5.1). | Fecal incontinence = 5(2%) total
| | 2nd stage labor > 1hour at 5 months 2.7(1.4, 5.0) | 1(3%) in those with tear
| | Use of oxytocin at 5 months 2.1(1.02, 4.2). | 4(2%) in no sphincter tear
| | Fundal pressure 2.3 at 5 months(1.3, 4.4) | No fecal incontinence = 73%, fecal incontinence < once per week = 1%, fecal incontinence > once per week = 0.5%
| | Instrumental delivery at 5 months 4.9(2.2, 10.8). | Prevalence of Fecal
| | Sphincter tear at 5 months 3.8(1.8, 8.1), at 9 months 2.4(1.1, 5.2). | Incontinence at 9 months after delivery
| | Lithotomy position at 5 months 3.2(1.2, 8.5). | Fecal incontinence = 3(1%) total
| | Fecal incontinence at 9 months risk factors per multivariate analysis. | 0 in sphincter tear women
| | Maternal age 3.0(1.4, 6.4), Sphincter 2.4(1.04, 4.9). | 3(1%) in no sphincter tear
| | | No fecal incontinence = 73%, fecal incontinence < once per week = 1%, fecal incontinence > once per week = 0
Galandiuk, 1991 ^299^ | 95 patients had a previous partial or subtotal colectomy (delayed IPAA group) Prior to a total chronic colectomy for ulcerative colitisstaged surgical procedure. | Level of risk appears dichotomous. | 3% of delayed IPAA group had severe incontinence during the day and 8% had severe incontinence at night
Retrospective chart review of delayed IPAA group of patients at Mayo Clinic, MN. | Method of Measurement:, no definition of FI was reported. 776 patients had an ideal pouch anastomosis at the time of a total colectomy (IPAA concurrent group). | Yes/no for delayed IPAA yes/no for IPAA concurrent | 3% of those with IPAA concurrent had severe incontinence during the day and 10% at night
N = 43 females | Definition of Risk Factors: Delayed or concurrent IPAA.
N = 52 males
Age: 14–60 years
(Average = 31 years)
Nelson, 2001 ^300^ | Data Source: Secondary analysis of data from 1992 (181 homes) and 1993 (177 homes)Wisconsin Center for Health Statistics Annual Nursing Home Survey | Correlates of UI | Urinary Incontinence:
Cross Sectional, Survey, secondary data analysis from Wisconsin nursing homes. | Definition of Incontinence: Urinary Incontinence; listed on MDS as being frequently or always incontinent. | 1992: Odds Ratio (95%CI) | 1992 = 53.9%
N = 18,170 (1992) | Fecal Incontinence; “defined in a manner similar to urinary incontinence”. | Fecal Incontinence 20.5 (18.6–22.6) | 1993 = 61%
N = 17,117 (1993) | Risk Factors were: age, gender, race, health indicators, body mass index in kg, history of heart disease, dementia, stroke, depression, vision impairment, arthritis, diabetes, constipation, diarrhea, fecal impaction, ulcers. | Trunk restraints: 2.5 (2.3–2.8) | Age of those with urinary incontinence:
71% female (1993) | Functional Status Indicators: ability to dress oneself, feed oneself, maintain personal hygiene, locomotion, mobility, use toilet transfer from bed to chair, tube feeding, trunk restraints. | Dementia 1.5 (1.4–1.7) | 1992 = 85.9 years
72% female (1992) | Age and BMI were continuous; all other risks were dichotomous | Impaired vision 1.4 (1.3–1.5) | 1993 = 85.2 years.
| | Stroke: 1.3 (1.2–1.4) | Age of continent residents:
| | Constipation (1.2–1.4) | 1992 = 84.4 years
| | Age 0.99 (0.98–0.99) | 1993 = 85.2 years
| | Diarrhea 0.7 (0.5–0.8) | Prevalence by Severity of Urinary Incontinence:
| | Male sex 0.8 (0.7–0.9) | 1992:
| | Correlates of Urinary Incontinence in 1993 | Occasionally = 8%
| | Fecal incontinence 17.8 (16.1–19.7) | Frequently = 15%
| | Trunk restraints 2.4 (2.1–2.7) | 1993
| | Dementia 1.5 (1.4–1.7) | Occasionally = 8.2%
| | Impaired vision 1.4 (1.3–1.6) | Frequently = 16.7%
| | Stroke 1.4 (1.2–1.5) | 1992: 93% Caucasian
| | Constipation 1.3 (1.2–1.4) | 1993: 95% Caucasian
| | Age 0.98 (0.98–0.99)
| | Diarrhea 0.7 (0.6–0.9)
| | Male sex 0.8 (0.7–0.8)
| | Tube feeding 0.7 (0.5–0.9)
Borrie, 1992 ^301^ | 474 bed long term care hospital in 1986 N = 457 patients (the majority (240) were male veterans), 447 questionnaires were returned. | Hierarchic regression was used: | Overall UI prevalence = 62%
Cross sectional study of long term care hospital in Canada. | Method of Measurement: nurse manager and primary nurse rated degree of patient's incontinence. | Step 1 = 10 most common diagnoses entered as a set. | Fecal incontinence = 46%
N = 447 | Definition of Incontinence: a condition in which involuntary loss of urine or feces is a social or hygienic problem and is objectively demonstrable | Step 2 = meds as a set. | Double incontinence = 44%
Average age: Male = 73.6 | Urinary/Fecal incontinence = 1–2 incontinent events per week or 3–7 events per week. | Step 3 = mobility and mental function. | UI in men = 61%
Female = 73.8 | | Mobility (4 levels): 1) independent, 2) supervised, 3) assistance, 4) immobile. | UI in females = 65%
27% female | | Mental impairment (4 levels): 1) none, 2) mild, 30 moderate, 4) severe. | Urinary incontinence:
| | | diagnosis accounted for 12% variance.
| | | F = 5.72 p <.001, meds for 5%
| | | F = 2.15 p <.05, mobility and mental impairment = 44%
| | | F = 207.0 p <.001
| | | For Fecal Incontinence diagnosis = 11% of variance
| | | F = 5.3 p <.001 meds = 5%
| | | F = 2.33 p <.01, mobility and mental function = 40%
| | | F = 202.2 p <.001
Mecocci, 2005 ^302^ | 81 community and university hospitals in Italy; data collected May–June and November–December for 5 years: N= 13,729 | Age = 3 categories | Prevalence of Incontinence:
Longitudinal, cross sectional study from hospitals in Italy. | Methods of Measurement: Questionnaire completed by study MD daily and chart review. | Length of stay in weeks = 3 categories | Urinary incontinence = 22.3%;
N = 13,729 | Definition of Incontinence: Incontinence had to be absent at admission and present at discharge; reported in patient's chart. | ADL = 3 categories | Males = 19.9%
Age: ≥65 | | Others yes/no | Females = 24.5%
Female = 73.3 | | | Cognitive impairment:
| | | 5.3(2.3–12.0)
| | | CVA = 2.4(1.1–5.3)
| | | Age > 85 years
| | | 3.2(1.1–9.8)
| | | Length of Stay >3 weeks
| | | 6.5(2.8–15.5)
| | | Totally dependent in ADL
| | | 2.9(1.1–7.6)
Jackson, 1997 ^303^ | Patients recruited from urogynecology and gynecology clinics of Cleveland Clinic Foundation; N = 247 F | All levels not reported but appear to be yes/no for UI and IBS | Prevalence of Incontinence
Patients recruited from clinics of Cleveland Clinic Foundation. | Methods of Measurement: Questionnaire and MD interview, | Sphincter tone levels; normal, diminished, absent. | Fecal incontinence: n = 42 (17%)
Average age: 53.3 (SD = 15.2 years) | Definition of Incontinence: Involuntary loss of feces sufficient to be considered a problem by the patient. | Correlates of fecal incontinence: urinary incontinence OR = 4.6 | Urinary incontinence: n = 100
N = 247 (91% white; 9% black) | 91% white, (n = 225), 9% black, (n = 22) | CI = 1.9, 11.2 | Double incontinence: n = 31
100% female | | IBS OR = 8.3
| | CI = 2.1–32.8
| | Abnormal sphincter tone;
| | OR = 2.3; 1.1,5.1
Endo, 2002 ^304^ | N = 929 patients records source: clinic records 1991-1999. | IADSs | Prevalence:
Retrospective analysis of patient records in a U.S. geriatric clinic (1991-1999). | Definition of Incontinence: Urinary incontinence; involuntary loss of urine sufficient to be a problem. | MMSE | Any urinary incontinence = 38.6% total; male = 30.6% female = 41.7%
Age: 78.6 (SD 6.5) | Fecal Incontinence; involuntary loss of stool sufficient to be a problem. | CIRS: | Isolated urinary incontinence = 34% total; male = 25.9% and female = 37.1%
96.1% White | Double Incontinence; urinary and fecal incontinence. | (cumulative illness rating scale and age were continuous variables | Any fecal incontinence = 11% total; male = 11.6% and female = 10.7%
2.7% Black | Isolated fecal incontinence; without urinary incontinence. | Serum B12 | Isolated fecal incontinence = 4.2% total, male = 5.6% and female = 3.6%
1.2% Other | Isolated urinary incontinence; without fecal incontinence. | 1 ≥300 pg/ml | Double incontinence = 12.5% total; male = 10.6% and female = 13.3%
N = 929 records | Any urinary incontinence; (with or without fecal incontinence). | 0 ≤300 pg/ml | Any incontinence = 41.2% total; male = 34.5% and female = 43.8%
72.2% female | | Medications = yes/no | Correlates of Incontinence
| | | Isolated urinary incontinence
| | | Factor = anticonvulsants
| | | OR (CI) = 4.529 (1.230–16.675)
| | | Factor = Diuretics
| | | OR (CI) = 1.481 (1.016–2.158)
| | | Factor = antihistamines
| | | OR (CI) = 1.909 (1.013–3.599)
| | | Factor = IADLS
| | | OR (CI) = 0.956 (.929–.984)
| | | Isolated Fecal incontinence
| | | Factor = modified CIRS
| | | OR (CI) = 1.204 (1.056–1.373)
| | | Factor = Biz level
| | | OR (CI) = 2.225 (1.243–3.982)
| | | Factor = IADLs
| | | OR (CI) = .821 (.777–.867)
| | | Factor = Cathartic/laxative use
| | | OR (CI) = 1.902 (1.078–3.355)
| | | Factor = Diuretic use
| | | OR (CI) = 2.226 (1.264–3.921)
Chassagne, 1999 ^305^ | Methods of Measurement: Medical records and observation. | Levels of risk were not reported | Baseline prevalence of Fecal incontinence = 1,416 residents 234 residents developed fecal incontinence over 296 days
Cross sectional projective study in 13 French long term care facilities. | Definition of Incontinence: “at least one involuntary loss of feces”. | Variables that were candidates for the multivariate regression analysis were not reported. | Cumulative incidence = 20%
Age: ≥60 years | “Long-lasting fecal incontinence was not defined”. | 234 with fecal incontinence 83.5 years mean (SD). | 5 risks were associated with fecal incontinence
N = 1,186. | Exclusion criteria: Fecal incontinence at start of surveillance. | 952 without fecal incontinence = 82.9 (8.7) years. | Urinary incontinence RR = 20 (CI = 1.5, 2.6)
% female unknown | | 171 females in those with fecal incontinence = 73%. | Presence of neurological disease RR = 1.9 (1.0, 3.4)
| | 669 females without fecal incontinence = 70%. | Poor Mobility RR = 1.7 (1.2, 2.4)
| | | MMSE < 15 RR = 1.4 (1.1, 1.9)
| | | Age > 70 years RR = 1.7 (1.0, 2.8)
| | | Risks for “long lasting” fecal incontinence history of urinary incontinence RR = 2.9 (1.8, 4.6)
| | | Decreased mobility RR = 1.8 (1.1, 3.0)
| | | MMSE score < 15 RR = (1.4, 4.4)
| | | History of dementia RR = 2.1 (1.2, 3.5)
| | | 68% of those with fecal incontinence had urinary incontinence
| | | 81% of those without fecal incontinence had urinary incontinence
Nelson, 1998 ^306^ | Methods of Measurement: MDS questions. | All variables except age and body mass index (BMI) were dichotomous. | Prevalence of Fecal Incontinence
Cross sectional, Minimum Data Set (MDS) data of Wisconsin nursing home residents in 1992 and 1993; nursing homes. | Definition of Incontinence: Fecal incontinence as; | Age and BMI were continuous. | 1992: 47% had fecal incontinence.
1992, N = 18,224 | 1 usually continent,; 2 occasionally incontinent,; 3 frequently incontinent,; 4 incontinent. | 1992: 71% = Fecal incontinence | 1993: 46% had fecal incontinence.
1993, N = 17,127 | Similar definition for urinary incontinence. | 1993: 72% female | Associations with Fecal Incontinence in Wisconsin Nursing Homes: Minimum Data Set Reports from 1992 to 1993
% female not reported | Number of residents: | Subject Race: 1992: | Urinary Incontinence:
| | | 1992- 12.6; 11.5–13.7
| | | 1993- 11.3; 10.3–12.4
| | | Tube feeding
| | | 1992- 7.6; 5.6–10.4
| | | 1993- 8.8; 6.3–12.3
| | | Loss of ADL
| | | 1992- 6.0;4.7–7.7
| | | 1993- 7.3; 5.5–9.7
| | | Diarrhea
| | | 1992-3.3; 2.7–4.2
| | | 1993-2.4; 1.9–3.1
| | | Trunk restraints
| | | 1992- 3.2; 4.7–7.7
| | | 1993- 3.0; 2.7–9.8
| | | Pressure Ulcer
| | | 1992- 2.6; 2.2–3.0
| | | 1993- 2.3;2.0–2.6
| | | Dementia
| | | 1992- 1.5; 1.4–1.7
| | | 1993- 1.4; 1.3–1.5
| | | Impaired Vision
| | | 1992- 1.5; 1.4–1.7
| | | 1993- 1.4; 1.3–1.5
| | | Fecal impaction
| | | 1992- 1.5; 1.1–2.1
| | | 1993- 2.1; 1.3–3.3
| | | Constipation
| | | 1992- 1.4; 1.3–1.6
| | | 1993- 1.3; 1.2–1.4
| | | Stroke
| | | 1992- 1.3; 1.2–1.5
| | | 1993- 1.2; 1.1–1.3
| | | Male Gender
| | | 1992- 1.2; 1.1–1.3
| | | 1993- 1.3; 1.1–1.4
| | | Non-Caucasian race
| | | 1992- NS
| | | 1993- 1.3; 1.0–1.7
| | | Age
| | | 1992; 1.1–1.01
| | | 1993; 1.0; 1.0–1.01
| | | Body mass index
| | | 1992- 1.0; 1.0–1.3
| | | 1993- 1.0; 1.0–1.04
| | | Diabetes
| | | 1992- NS
| | | 1993- NS
| | | Heart disease
| | | 1992- 0.9; 0.8–1.0
| | | 1993- NS
| | | Arthritis
| | | 1992- 0.9; 0.8–1.0
| | | 1993- 0.8; 0.7–0.9
| | | Depression
| | | 1992- NS
| | | 1993- 0.9; 0.8–1.0
| | | NS = not statistically significant
Eason, 2002 ^283^ | Target population of pregnant women who gave birth in 5 Quebec hospitals in 1995-1996 and had previously participated in a study of perineal massage.
Cross sectional study in Quebec hospitals | Method of Measurement: 1,198 received a mailed questionnaire 3 months after delivery..
N = 949
100% female
DeLeeuw, 2001 ^307^ | 171 women who underwent primary repair of a 3rd and 4th degree perineal rupture between Jan 1971 and Dec 1990 were eligible as cases; controls were women matched for parity to cases who had a vaginal delivery without anal sphincter damage in the same hospital. | Candidate variables: | Prevalence of complaints
Retrospective cohort, comparative study of women in a Netherlands Hospital. | Sample of 125 case and control pairs. | Extent of anal sphincter damage 3 levels: 1) partial rupture, 2) complete rupture with intact mucosa, and 3) complete rupture of sphincters mucosa. | Anorectal complaints
Median age at delivery: | Method of Measurement: Postal questionnaire and surgical records | Presence of medio-lateral episiotomy, (yes/no). | Cases (n = 125) = 50 (40)
Cases; 26 (18–41) | Definition of Incontinence: Parks classification of fecal incontinence | Subsequent vaginal delivery, (yes/no). | Controls (n = 125) = 19 (15)
Control: 28 (19–38) | | | Mantel-Haenzel common
N = 125 pairs | | | Odds-Ratio [95%-CI] = 3.64 [1.87–7.09]
100% female | | | Fecal Incontinence
| | | Cases (n = 125) = 39 (31)
| | | Controls (n = 125) = 16 (13)
| | | Mantel-Haenzel common
| | | Odds-Ratio [95%-CI] = 3.09 [1.57–6.10]
| | | Grade-II
| | | Cases (n = 125) = 28 (22)
| | | Controls (n = 125) = 14 (11)
| | | Grade-III
| | | Cases (n = 125) = 10 (8)
| | | Controls (n = 125) = 2 (2)
| | | Grade-IV
| | | Cases (n = 125) = 1 (1)
| | | Controls (n = 125) = 0
| | | Fecal urgency
| | | Cases (n = 125) = 32 (36)
| | | Controls (n = 125) = 7 (6)
| | | Mantel-Haenzel common
| | | Odds-Ratio [95%-CI] = 7.25 [2.55–20.62]
| | | Fecal soiling
| | | Cases (n = 125) = 12 (10)
| | | Controls (n = 125) = 1 (1)
| | | Mantel-Haenzel common
| | | Odds-Ratio [95%-CI] = 12.00 [1.56–92.29]
| | | Urinary incontinence
| | | Cases (n = 125) = 65 (52)
| | | Controls (n = 125) = 52 (42)
| | | Mantel-Haenzel common
| | | Odds-Ratio [95%-CI] = 1.46 [0.91–2.37]
| | | Stress-incontinence
| | | Cases (n = 125) = 63 (50)
| | | Controls (n = 125) = 50 (40)
| | | Mantel-Haenzel common
| | | Odds-Ratio [95%-CI] = 1.46 [0.91–2.37]
| | | Urge-incontinence
| | | Cases (n = 125) = 32 (26)
| | | Controls (n = 125) = 28 (22)
| | | Mantel-Haenzel common
| | | Odds-Ratio [95%-CI] = 1.16 [0.68–1.98]
| | | Results are odds ratio and confidence interval for multivariate analysis: extent of perineal damage = 2.54 (1.45– 4.45)
| | | Mediolateral episiotomy in primiparous women .17 (.05– .61)

Table F1g Evidence tables of the association between risk factors and prevalence of fecal incontinence in adults in the community and in long-term care settings

Author, Study Design Adjustment for Confounding Factors | Subject election, Data Source, Measurement Methods, Definitions | Subject Age, Gender | Levels of Risk Factors | | Prevalence and Incidence of FI and UI Incontinence, Odds Ratio
Bliss,2004 ^308^ | 1,352 elderly subjects selection: Elderly visiting HMO Clinics | Mean age (SD) = 75(6) | Amount of leakage: | | Overall prevalence = 26.3% 19% had FI ≥1/year;
Design | Methods to measure incontinence: survey distributed at clinics | 60% female | Soils underwear, outerwear or shoes/floor | | 1.5% had daily FI Prevalence of double incontinence = 1.7%
Cross sectional | Definition of FI: accidental stool leakage during past 12 mos. | | FI frequency: ≥1/day
Adjustment for confounding factors: | Severity/type: amount of leakage | | Several times per week
Numerous; age, sex etc. | Type of leakage | | Several times per month
| Frequency of leakage | | One or more times per year
| | | Type: loose/liquid, formed, mucus
| | | Freq, Type, Amount Risk Factors with Cut Offs | | Odds Ratio
| | | Solid | urgency always | 20 (2.9; 11)
| | | | urgency most times | 4.3 (0.9; 17)
| | | Loose liquid | hemorrhoid surgery | 2.5 (1.4; 4.3
| | | | urgency most times | 3.1 (1.7; 5.8)
| | | | urgency sometimes | 2.1 (1.4; 3.2)
| | | | loose liquid stool | 2.8 (1.3; 6.1)
| | | | Ref is no FI | 1 (1; 1)
| | | Severity, frequency ≥1/day | loose or liquid stool | 2.4 (1.3; 4.3)
| | | | bowel resection | 3.2 (1.5; 6.6)
| | | | hemorrhoids | 1.6 (1.1; 2.3)
| | | Frequency ≥1/day | stool softener for constipation | 2.1 (1.1; 3.7)
| | | | Urinary incontinence | 2.5 (1.8; 3.4)
| | | | self rate health as poor | 1.2 (1; 1.4)
| | | | urgency always | 11 (5.1; 26)
| | | | urgency most times | 4.7 (2.8; 7.6)
| | | | urgency sometime | 3 (2.1; 4.3)
| | | Severity amount | Ref is no FI | 1 (1; 1)
| | | | loose liquid stool | 3 (1.5; 5.8)
| | | | bowel resection | 2.2 (1.1; 4.5)
| | | | mild memory problems | 2.1 (1.4; 3)
| | | | Moderate/severe memory problems | 2.3 (1.4; 3.9)
| | | | low back pain or sciatica | 1.5 (1.1; 2.1)
| | | | hemorrhoids | 1.5 (1.1; 2.1)
| | | | overweight | 1.4 (1; 2)
| | | | urgency sometime | 2.8 (2; 4.1)
| | | | urgency most times | 5 (3; 8.6)
| | | | urgency always | 12 (4.9; 29)

Table F2 Prevalence of UI in community dwelling males by country, type, and definition of UI (the results from individual studies)

Author | Location | Age | N | Prevalence (%) 95%CI
Total
Van Oyen, 2002 ^157^ | Belgium | 15–24 | 443 | 0.1 (0.10; 0.10)
Temml, 1999 ^170^ | Austria | 20–29 | 59 | 1.7 (1.67; 1.73)
Diokno, 2007 ^89^ | USA | 18–34 | 3,177 | 7.25 (7.24; 7.26)
Andersson, 2004 ^10^ | Sweden | 18–34 | 9,836 | 3 (3.00; 3.00)
Van Oyen, 2002 ^157^ | Belgium | 25–34 | 680 | 0 (0.00; 0.00)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | <39 | 2,792 | 2.4 (2.39; 2.41)
Schulman, 1997 ^192^ | Belgium | 30–34 | 2,499 | 0.8 (0.80; 0.80)
Smoger, 2000 ^169^ | USA | <40 | 67 | 25.4 (25.30; 25.50)
Temml, 2000 ^170^ | Austria | 30–39 | 184 | 2.7 (2.68; 2.72)
Schulman, 1997 ^192^ | Belgium | 35–39 | 2,499 | 2.6 (2.59; 2.61)
Brocklehurst, 1993 ^199^ | Great Britain | 30–49 | 867 | 2 (1.99; 2.01)
Diokno, 2007 ^89^ | USA | 35–44 | 4,295 | 7.17 (7.16; 7.18)
O'Brien, 1991 ^309^ | UK | 35–44 | 576 | 2.4 (2.39; 2.41)
Van Oyen, 2002 ^157^ | Belgium | 35–44 | 705 | 0.6 (0.59; 0.61)
Lagace, 1993 ^200^ | USA | >20 | 922 | 11.3 (11.28; 11.32)
Schulman, 1997 ^192^ | Belgium | 40–44 | 2,499 | 2 (1.99; 2.01)
Andersson, 2004 ^10^ | Sweden | 35–49 | 9,836 | 6 (6.00; 6.00)
MacLennan, 2000 ^84^ | Australia | 15–97 | 1,464 | 4.4 (4.39; 4.41)
Temml, 2000 ^170^ | Austria | 40–49 | 458 | 3.9 (3.88; 3.92)
Ueda, 2000 ^172^ | Japan | 40–49 | 180 | 5 (4.97; 5.03)
Malmsten, 1997 ^188^ | Sweden | 45 | 1,151 | 3.6 (3.59; 3.61)
Smoger, 2000 ^169^ | USA | 41–50 | 165 | 30.9 (30.83; 30.97)
Schulman, 1997 ^192^ | Belgium | 45–49 | 2,499 | 2.3 (2.29; 2.31)
Roe, 2000 ^168^ | UK | 18–98 | 2,660 | 5.3 (5.29; 5.31)
Temml, 2005 ^310^ | USA | 20–91 | 1,199 | 1.8 (1.79; 1.81)
Andersson, 2004 ^10^ | Sweden | 18–79 | 9,836 | 10 (9.99; 10.01)
Temml, 2000 ^170^ | Austria | 20–96 | 1,236 | 5 (4.99; 5.01)
Schmidbauer, 2001 ^62^ | Austria | 20–91 | 1,236 | 5 (4.99; 5.01)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >18 | 8,130 | 5.4 (5.40; 5.40)
Diokno, 2007 ^89^ | USA | 45–54 | 4,510 | 10.98 (10.97; 10.99)
O'Brien, 1991 ^309^ | UK | 45–54 | 511 | 5.5 (5.48; 5.52)
Van Oyen, 2002 ^157^ | Belgium | 45–54 | 599 | 0.9 (0.89; 0.91)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | 40–59 | 3,096 | 5.2 (5.19; 5.21)
Malmsten, 1997 ^188^ | Sweden | 50 | 945 | 4.1 (4.09; 4.11)
Schulman, 1997 ^192^ | Belgium | 50–54 | 2,499 | 4.9 (4.89; 4.91)
Brocklehurst, 1993 ^199^ | Great Britain | >30 | 1,883 | 6.6 (6.59; 6.61)
Schulman, 1997 ^192^ | Belgium | >30 | 2,499 | 5.2 (5.19; 5.21)
Temml, 2000 ^170^ | Austria | 50–59 | 294 | 3.7 (3.68; 3.72)
Brocklehurst, 1993 ^199^ | Great Britain | 50–59 | 315 | 5.4 (5.38; 5.42)
Ueda, 2000 ^172^ | Japan | 50–59 | 197 | 6.6 (6.57; 6.63)
Roberts, 1998 ^311^ | USA | 50–59 | 225 | 16.9 (16.85; 16.95)
O'Brien, 1991 ^309^ | UK | >35 | 2,496 | 7.4 (7.39; 7.41)
Malmsten, 1997 ^188^ | Sweden | 55 | 779 | 3.3 (3.29; 3.31)
Bortolotti, 2000 ^165^ | Italy | 51–60 | 1,222 | 2 (1.99; 2.01)
Smoger, 2000 ^169^ | USA | 51–60 | 137 | 31.4 (31.32; 31.48)
Schulman, 1997 ^192^ | Belgium | 55–59 | 2,499 | 4.9 (4.89; 4.91)
Andersson, 2004 ^10^ | Sweden | 50–64 | 9,836 | 13 (12.99; 13.01)
Umlauf, 1996 ^195^ | USA | 52–64 | 223 | 20 (19.95; 20.05)
Ueda, 2000 ^172^ | Japan | 40–80 | 818 | 10.5 (10.48; 10.52)
Diokno, 2007 ^89^ | USA | 55–64 | 3,113 | 15.58 (15.57; 15.59)
O'Brien, 1991 ^309^ | UK | 55–64 | 584 | 5.7 (5.68; 5.72)
Van Oyen, 2002 ^157^ | Belgium | 55–64 | 428 | 2.7 (2.68; 2.72)
Roberts, 1998 ^311^ | USA | 40–79 | 2,150 | 17.3 (17.28; 17.32)
Boyle, 2003 ^121^ | France | 40–79 | 1,217 | 7.8 (7.78; 7.82)
| Netherlands | 40–79 | 1,233 | 16.2 (16.18; 16.22)
| UK | 40–79 | 990 | 14 (13.98; 14.02)
| South Korea | 40–79 | 1,360 | 10 (9.98; 10.02)
Smoger, 2000 ^169^ | USA | 25–93 | 809 | 32.3 (32.27; 32.33)
| | 25–93 | 660 | 32 (31.96; 32.04)
| | 25–93 | 133 | 33.1 (33.02; 33.18)
| | 25–93 | 11 | 36.4 (36.16; 36.64)
Aggazzotti, 2000 ^163^ | Italy | <65 | 217 | 19.1 (19.05; 19.15)
Perry, 2000 ^312^ | UK | >40 | 6,941 | 8.9 (8.89; 8.91)
Malmsten, 1997 ^188^ | Sweden | 60 | 775 | 5.1 (5.08; 5.12)
McGrother, 2003 ^26^ | UK | >40 | 42,939 | 14.2 (14.20; 14.20)
Teunissen, 2004 ^119^ | Netherlands | 60–64 | 2,137 | 5 (4.99; 5.01)
Schulman, 1997 ^192^ | Belgium | 60–64 | 2,499 | 5.5 (5.49; 5.51
Stothers, 2005 ^116^ | USA | 60–64 | 5,037,678 | 11 (11.00; 11.00)
Roberts, 1998 ^311^ | USA | >50 | 766 | 26.4 (26.37; 26.43)
Goluboff, 1998 ^313^ | Columbia | | 480 | 13.1 (13.07; 13.13)
Malmsten, 1997 ^188^ | Sweden | 45–99 | 7,763 | 9.2 (9.19; 9.21)
Temml, 1999 ^170^ | Austria | 60–69 | 132 | 7.6 (7.56; 7.64)
Ueda, 2000 ^172^ | Japan | 60–69 | 281 | 11.4 (11.36; 11.44)
Roberts, 1998 ^311^ | USA | 60–69 | 270 | 23.7 (23.65; 23.75)
Diokno, 1990 ^314^ | USA | 60–69 | 489 | 18.2 (18.17; 18.23)
Koyama, 1998 ^177^ | Japan | 60–69 | 308 | 1.3 (1.29; 1.31)
Bortolotti, 2000 ^165^ | Italy | >50 | 2,721 | 3.4 (3.39; 3.41)
Jorgensen, 2005 ^114^ | Norway | 31–93 | 136 | 4 (3.97; 4.03)
Malmsten, 1997 ^188^ | Sweden | 65 | 739 | 6.1 (6.08; 6.12)
Bogren, 19979464154 | Sweden | 65 | 233 | 9 (8.96; 9.04)
Bortolotti, 2000 ^165^ | Italy | 61–70 | 768 | 2.6 (2.59; 2.61)
Smoger, 2000 ^169^ | USA | 61–70 | 237 | 36.3 (36.24; 36.36)
Teunissen, 2004 ^119^ | Netherlands | 65–69 | 2,137 | 6 (5.99; 6.01)
Stoddart, 2001 ^162^ | Great Britain | 65–69 | 167 | 12 (11.95; 12.05)
Schulman, 1997 ^192^ | Belgium | 65–69 | 2,499 | 8.5 (8.4; 8.51)
Maggi, 2001 ^158^ | Italy | 65–69 | 867 | 4.6 (4.59; 4.61)
Stothers, 2005 ^116^ | USA | 65–69 | 4,731,187 | 11 (11.00; 11.00)
Haltbakk, 2005 ^315^ | Norway | 39–91 | 480 | 36.7 (36.66; 36.74)
Brocklehurst, 1993 ^199^ | Great Britain | 60+ | 701 | 13.3 (13.27; 13.33)
Teunissen, 2004 ^119^ | Netherlands | >60 | 2,137 | 9 (8.99; 9.01)
Tseng, 2000 ^171^ | Taiwan | <70 | 65 | 13.8 (13.72; 13.88)
| | >70 | 181 | 15.5 (15.45; 15.55)
Adolfsson, 1998 ^252^ | Sweden | 50–80 | 656 | 20.6 (20.57; 20.63)
Joly, 1998 ^316^ | Netherlands | 51–82 | 65 | 9 (8.93; 9.07)
Jitapunkul, 1998 ^182^ | Thailand | >60 | 232 | 16.81 (16.76; 16.86)
Diokno, 2007 ^89^ | USA | 65–74 | 2,260 | 23.82 (23.80; 23.84)
Aggazzotti, 2000 ^163^ | Italy | 65–74 | 217 | 22.7 (22.64; 22.76)
O'Brien, 1991 ^309^ | UK | 65–74 | 506 | 12.1 (12.07; 12.13)
Umlauf, 1996 ^195^ | USA | 65–74 | 724 | 26 (25.97; 26.03)
Van Oyen, 2002 ^157^ | Belgium | 65–74 | 384 | 5.2 (5.18: 5.22)
Herzog, 1990 ^41^ | USA | >60 | 802 | 18.8 (18.77; 18.83)
Diokno, 1990 ^314^ | USA | >60 | 802 | 18.8 (18.77: 18.83)
Diokno, 1991 ^317^ | USA | >60 | 655 | 20.2(20.17; 20.23)
Sgadari, 1997 ^40^ | Denmark | >60 | 1,799 | 51.2 (51.18; 51.22)
| France | >60 | 167 | 46 (45.93; 46.07)
| Iceland | >60 | 377 | 64.4 (64.35; 64.45)
| Italy | >60 | 586 | 36 (35.96; 36.04)
| Japan | >60 | 539 | 51.6 (51.56; 51.64)
| Sweden | >60 | 436 | 61.4 (61.35; 61.45)
| USA | >60 | 12,6070 | 44.5 (44.50; 44.50)
Van Oyen, 2002 ^157^ | Belgium | >15 | 3,462 | 1.4 (1.40; 1.40)
Malmsten, 1997 ^188^ | Sweden | 70 | 776 | 7.3 (7.28; 7.32)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >60 | 2,029 | 10.4 (10.39; 10.41)
Ouslander, 1990 ^318^ | USA | | 60 | 37 (36.88; 37.12)
Umlauf1996 ^195^ | USA | 52–99 | 1,490 | 29 (28.98; 29.02)
Teunissen, 2004 ^119^ | Netherlands | 70–74 | 2,137 | 8 (7.99; 8.01)
Stoddart, 2001 ^162^ | Great Britain | 70–74 | 194 | 21.1 (21.04; 21.16)
Maggi, 2001 ^158^ | Italy | 70–74 | 867 | 12.6 (12.58; 12.62)
Stothers, 2005 ^116^ | USA | 70–74 | 3,320,840 | 19 (19.00; 19.00)
Andersson, 2004 ^10^ | Sweden | 65–79 | 9,836 | 21 (20.99; 21.01)
Schulman, 1997 ^192^ | Belgium | 70+ | 2,499 | 13.8 (13.79; 13.81)
Tseng, 2000 ^171^ | Taiwan | >65 | 248 | 15 (14.96; 15.04)
Damian, 1998 ^176^ | Spain | >65 | 589 | 14.5 (14.47; 14.53)
Stothers, 2005 ^116^ | USA | >65 | 1,8231,934 | 17 (17.00; 17.00)
Nakanishi, 1997 ^190^ | Japan | >65 | 1,405 | 8.7 (8.69; 8.71)
Ju, 1991 ^205^ | Singapore | >65 | 435 | 4.4 (4.38; 4.42)
Borrie, 1992 ^301^ | Canada | | 326 | 61 (60.95; 61.05)
Roberts, 1998 ^311^ | USA | 70–79 | 217 | 35.9 (35.84; 35.96)
Diokno, 1990 ^319^ | USA | 70–79 | 229 | 18.8 (18.75; 18.85)
Koyama, 1998 ^177^ | Japan | 70–79 | 378 | 8 (7.97; 8.03)
Bortolotti, 2000 ^165^ | Italy | >70 | 731 | 6.6 (6.58; 6.62)
Ueda, 2000 ^172^ | Japan | >70 | 160 | 20 (19.94; 20.06)
Stoddart, 2001 ^162^ | Great Britain | >65 | 781 | 23.4 (23.37; 23.43)
Malmsten, 1997 ^188^ | Sweden | 75 | 583 | 9.6 (9.58; 9.62)
Maggi, 2001 ^158^ | Italy | >65 | 867 | 11.5 (11.48; 11.52)
Smoger, 2000 ^169^ | USA | 71–80 | 178 | 33.2 (33.13; 33.27)
Koyama, 1998 ^177^ | Japan | >60 | 856 | 6.1 (6.08; 6.12)
Nuotio, 2003, ^136^ | Finland | >70 | 171 | 25 (24.94; 25.06)
Iglesias, 2000 ^167^ | Spain | >65 | 341 | 32.3 (32.25; 32.35)
Teunissen, 2004 ^119^ | Netherlands | 75–79 | 2,137 | 14 (13.99; 14.01)
Stoddart, 2001 ^162^ | Great Britain | 75–79 | 198 | 22.2 (22.14; 22.26)
Maggi, 2001 ^158^ | Italy | 75–79 | 867 | 12.3 (12.28; 12.32)
Stothers, 2005 ^116^ | USA | 75–79 | 2,748,396 | 27 (27.00; 27.00)
Kutner, 1994 ^197^ | USA | >65 | 113 | 4.5 (4.46; 4.54)
Stenzelius, 2004 ^54^ | Sweden | 75–79 | 655 | 31.2 (31.16; 31.24)
O'Brien, 1991 ^309^ | UK | >75 | 319 | 15.4 (15.36; 15.44)
Van Oyen, 2002 ^157^ | Belgium | >75 | 223 | 13.3 (13.26; 13.34)
Adelmann, 2004 ^50^ | USA | >65 | 163 | 25.8 (25.73; 25.87)
| | >65 | 22 | 13.6 (13.47; 13.73)
| | >65 | 100 | 72 (71.91; 72.09)
Langa, 2002 ^82^ | USA | >70 | 2,812 | 13 (12.99; 13.01)
Aggazzotti, 2000 ^163^ | Italy | 75–84 | 217 | 51.8 (51.73; 51.87)
Umlauf, 1996 ^195^ | USA | 75–84 | 452 | 38 (37.96; 38.04)
Malmsten, 1997 ^188^ | Sweden | 80 | 360 | 19.7 (19.66; 19.74)
Temml, 2005 ^310^ | USA | >70 | 106 | 5.7 (5.66; 5.74)
Maggi, 2001 ^158^ | Italy | 80–84 | 867 | 22.2 (22.17; 22.23)
Aggazzotti, 2000, ^163^ | Italy | 33–102 | 217 | 39.2 (39.14; 39.26)
Stothers, 2005 ^116^ | USA | 80–84 | 1,478,414 | 27 (27.00; 27.00)
Stenzelius, 2004 ^54^ | Sweden | 80–84 | 554 | 32.5 (32.46; 32.54)
Stoddart, 2001 ^162^ | Great Britain | >80 | 222 | 34.2 (34.14; 34.26)
Roberts, 1998, ^311^ | USA | >80 | 54 | 40.7 (40.57; 40.83)
Boyington, 2007 ^43^ | Southeastern USA | >65 | 22,539 | 72.2 (72.19; 72.21)
Temml, 1999 ^170^ | Austria | >70 | 109 | 15.6 (15.53; 15.67)
Stenzelius2004 ^54^ | Sweden | >75 | 1,642 | 34.8 (34.78; 34.82)
Brandeis, 1997 ^186^ | USA | 60–105 | 474 | 24.1 (24.06; 24.14)
Teunissen, 2004 ^119^ | Netherlands | >80 | 2,137 | 21 (20.98; 21.02)
Diokno, 1990 ^319^ | USA | >80 | 85 | 22.4 (22.31; 22.49)
Koyama, 1998 ^177^ | Japan | >80 | 170 | 10.6 (10.55; 10.65)
Diokno, 2007 ^89^ | USA | 75–97 | 1,386 | 30.19 (30.17; 30.21)
Smoger, 2000 ^169^ | USA | 80–93 | 25 | 20 (19.85; 20.15)
Malmsten, 1997 ^188^ | Sweden | 85–89 | 1,279 | 21.8 (21.78; 21.82)
Stenzelius, 2004 ^54^ | Sweden | 85–89 | 300 | 43.6 (43.54; 43.66)
Stothers, 2005 ^116^ | USA | >85 | 915,419 | 31 (31.00; 31.00)
Aggazzotti, 2000 ^163^ | Italy | 85–94 | 217 | 52.4 (52.33; 52.47)
Umlauf, 1996 ^195^ | USA | 85–94 | 51 | 31 (30.88; 31.12)
Maggi, 2001 ^158^ | Italy | >85 | 867 | 23.6 (23.57; 23.63)
Stenzelius, 2004 ^54^ | Sweden | >90 | 133 | 41.9 (41.82; 41.98)
Malmsten, 1997 ^188^ | Sweden | 90–99 | 376 | 28.2 (28.15; 28.25)
Aggazzotti, 2000 ^163^ | Italy | 95+ | 217 | 57.1 (57.03; 57.17)
Umlauf, 1996 ^195^ | USA | 95–99 | 3 | 66 (65.65; 66.35)
Mixed
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | <39 | 2,500 | 0.4 (0.40; 0.40)
MacLennan, 2000 ^84^ | Australia | 15–97 | 1,464 | 1 (0.99; 1.01)
Ueda, 2000 ^172^ | Japan | 40–49 | 180 | 0 (0.00; 0.00)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >18 | 8,167 | 0.6 (0.60; 0.60)
| | 40–59 | 3,000 | 0.4 (0.40; 0.40)
Diokno, 2007 ^89^ | USA | 18–97 | 21,590 | 1.8 (1.80; 1.80)
Ueda, 2000 ^172^ | Japan | 50–59 | 197 | 0.4 (0.39; 0.41)
| | 40–80 | 818 | 1.5 (1.49; 1.51)
| | 60–69 | 281 | 0.7 (0.69; 0.71)
Diokno, 1990 ^319^ | USA | 60–69 | 489 | 5.3 (5.28; 5.32)
Bortolotti, 2000 ^165^ | Italy | >50 | 2,721 | 20 (19.98; 20.02)
Roberts, 1998 ^311^ | USA | >50 | 775 | 6.7 (6.68; 6.72)
Jitapunkul, 1998 ^182^ | Thailand | >60 | 232 | 1.72 (1.70; 1.74)
Diokno, 1990 ^319^ | USA | >60 | 802 | 5.5 (5.48; 5.52)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >60 | 2,250 | 1.2 (1.20; 1.20)
Umlauf, 1996 ^195^ | USA | 52–99 | 1,490 | 13.1 (13.08; 13.12)
Damian, 1998 ^176^ | Spain | >65 | 589 | 2.3 (2.29; 2.31)
Ju, 1991 ^205^ | Singapore | >65 | 435 | 0 (0.00; 0.00)
Diokno, 1990 ^319^ | USA | 70–79 | 229 | 4.4 (4.37; 4.43)
Ueda, 2000 ^172^ | Japan | >70 | 160 | 0.4 (0.39; 0.41)
Nuotio, 2003 ^136^ | Finland | >70 | 171 | 6 (5.96; 6.04)
Diokno, 1990 ^319^ | USA | >80 | 85 | 9.4 (9.34; 9.46)
Stress
Maral, 2001 ^159^ | Turkey | 15–24 | 273 | 0 (0.00; 0.00)
| Turkey | 25–34 | 182 | 0 (0.00; 0.00)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | <39 | 3,000 | 0.1 (0.10; 0.10)
Maral, 2001 ^159^ | Turkey | 35–44 | 235 | 0.9 (0.89; 0.91)
MacLennan, 2000 ^84^ | Australia | 15–97 | 1,464 | 1.5 (1.49; 1.51)
Ueda, 2000 ^172^ | Japan | 40–49 | 180 | 0.2 (0.19; 0.21)
Engstrom, 2003 ^125^ | UK | 40–49 | 687 | 1 (0.99; 1.01)
Muscatello, 2001 ^160^ | Australia | 41–49 | 232 | 7 (6.97; 7.03)
Maral, 2001 ^159^ | Turkey | >15 | 1,000 | 1 (0.99; 1.01)
Temml, 1999 ^170^ | Austria | 20–96 | 1,236 | 1.5 (1.49; 1.51)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >18 | 8,167 | 0.6 (0.60; 0.60)
Mozes, 1997 ^189^ | Israel | 45–54 | 363 | 0.3 (0.29; 0.31)
Maral, 2001 ^159^ | Turkey | 45–54 | 169 | 1.2 (1.18; 1.22)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | 40–59 | 2,833 | 0.6 (0.60; 0.60)
Diokno, 2007 ^89^ | USA | 18–97 | 21,590 | 2.4 (2.40; 2.40)
Muller, 2005 ^320^ | USA | 30–70 | 1,001 | 2 (1.99; 2.01)
Corcos, 200 ^12^ | Canada | >35 | 1,566 | 0.8 (0.80; 0.80)
Ueda, 2000 ^172^ | Japan | 50–59 | 197 | 0.5 (0.49; 0.51)
Muscatello, 2001 ^160^ | Australia | 50–59 | 232 | 2 (1.98; 2.02)
Engstrom, 2003 ^125^ | UK | 50–59 | 717 | 2 (1.99; 2.01)
| UK | 40–80 | 2,217 | 2 (1.99; 2.01)
Mozes, 1997 ^189^ | Israel | 45–75 | 896 | 2.1 (2.09; 2.11)
Ueda, 2000 ^172^ | Japan | 40–80 | 818 | 1.3 (1.29; 1.31)
Mozes, 1997 ^189^ | Israel | 55–64 | 241 | 2.9 (2.88; 2.92)
Maral, 2001 ^159^ | Turkey | 55–64 | 80 | 3.8 (3.76; 3.84)
Muscatello, 2001 ^160^ | Australia | >40 | 232 | 9 (8.96; 9.04)
Koskimaki, 1998 ^178^ | Finland | 50–70 | 2,128 | 9 (8.99; 9.01)
Goepel, 2001 ^321^ | Germany | >40 | 211,648 | 11.6 (11.60; 11.60)
Ueda, 2000 ^172^ | Japan | 60–69 | 281 | 0.5 (0.49; 0.51)
Muscatello, 2001 ^160^ | Australia | 60–69 | 232 | 25 (24.94; 25.06)
Diokno, 1990 ^319^ | USA | 60–69 | 489 | 1.4 (1.39; 1.41)
Engstrom, 2003 ^125^ | UK | 60–69 | 465 | 4 (3.98; 4.02)
Bortolotti, 2000 ^165^ | Italy | >50 | 2,721 | 6 (5.99; 6.01)
Roberts, 1998 ^183^ | USA | >50 | 775 | 0.9 (0.89; 0.91)
Jitapunkul, 1998 ^182^ | Thailand | >60 | 232 | 0.43 (0.42; 0.44)
Mozes, 1997 ^189^ | Israel | 65–75 | 293 | 3.8 (3.78; 3.82)
Diokno, 1990 ^319^ | USA | >60 | 802 | 1.4 (1.39; 1.41)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >60 | 1,813 | 1.6 (1.59; 1.61)
Umlauf, 1996 ^195^ | USA | 52–99 | 1,490 | 0.5 (0.50; 0.50)
Tseng, 2000 ^171^ | Taiwan | >65 | 248 | 1.2 (1.19; 1.21)
Damian, 1998 ^176^ | Spain | >65 | 589 | 1.5 (1.49; 1.51)
Maral, 2001 ^159^ | Turkey | >65 | 61 | 4.9 (4.85; 4.95)
Diokno, 1990 ^319^ | USA | 70–79 | 229 | 1.7 (1.68; 1.72)
Ueda, 2000 ^172^ | Japan | >70 | 160 | 0.1 (0.10; 0.10)
Muscatello, 2001 ^160^ | Australia | >70 | 232 | 11 (10.96; 11.04)
Engstrom, 2003 ^125^ | UK | 70–80 | 348 | 5 (4.98; 5.02)
Koyama, 1998 ^177^ | Japan | >60 | 856 | 0.7 (0.69; 0.71)
Nuotio, 2003 ^136^ | Finland | >70 | 171 | 2 (1.98; 2.02)
Diokno, 1990 ^319^ | USA | >80 | 85 | 0 (0.00; 0.00)
Urge
Maral, 2001 ^159^ | Turkey | 15–24 | 273 | 1.1 (1.09; 1.11)
| Turkey | 25–34 | 182 | 0 (0.00; 0.000
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | <39 | 2,500 | 0.4 (0.40; 0.40)
Corcos, 2004 ^12^ | Canada | 35–44 | 591 | 11.1 (11.07; 11.13)
Maral, 2001 ^159^ | Turkey | 35–44 | 235 | 1.3 (1.29; 1.31)
MacLennan, 2000 ^84^ | Australia | 15–97 | 1,464 | 1.9 (1.89; 1.91)
Ueda, 2000 ^172^ | Japan | 40–49 | 180 | 0.9 (0.89; 0.91)
Engstrom, 2003 ^125^ | UK | 40–49 | 687 | 1 (0.99; 1.01)
Muscatello, 2001 ^160^ | Australia | 41–49 | 232 | 7 (6.97; 7.03)
Maral, 2001 ^159^ | Turkey | >15 | 1,000 | 2.7 (2.69; 2.71)
Temml, 1999 ^170^ | Austria | 20–96 | 1,236 | 2.7 (2.69; 2.71)
Moorthy, 2003 ^118^ | Asia (China, Hong Kong, India, Indonesia, Malaysia, Pakistan, Philippines, Singapore, South Korea, Taiwan, and Thailand) | >18 | 2,369 | 13 (12.99; 13.01)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >18 | 8583 | 1.2 (1.20; 1.20)
Corcos, 2004 ^12^ | Canada | 45–54 | 4,63 | 14.3 (14.27; 14.33)
Maral, 2001 ^159^ | Turkey | 45–54 | 169 | 3.6 (3.57; 3.63)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | 40–59 | 3,154 | 1.3 (1.30; 1.30)
Diokno, 2007 ^89^ | USA | 18–97 | 21,590 | 4.3 (4.30; 4.30)
Stewart, 2002 ^141^ | USA | >18 | 2,469 | 2.6 (2.59; 2.61)
Ueda, 2000 ^172^ | Japan | 50–59 | 197 | 0.7 (0.69; 0.71)
Muscatello, 2001 ^160^ | Australia | 50–59 | 232 | 2 (1.98; 2.02)
Engstrom, 2003 ^125^ | UK | 50–59 | 717 | 5 (4.98; 5.02)
Lee, 1998 ^322^ | Korea | 50–59 | 232 | 9.9 (9.86; 9.94)
Engstrom, 2003 ^125^ | UK | 40–80 | 2,217 | 6 (5.99; 6.01)
Ueda, 2000 ^172^ | Japan | 40–80 | 818 | 7.7 (7.68; 7.72)
Corcos, 2004 ^12^ | Canada | 55–64 | 265 | 17.5 (17.45; 17.55)
Maral, 2001 ^159^ | Turkey | 55–64 | 80 | 11.3 (11.23; 11.37)
Muscatello, 2001 ^160^ | Australia | >40 | 232 | 9 (8.96; 9.04)
Koskimaki, 1998 ^178^ | Finland | 50–70 | 2,128 | 17 (16.98; 17.02)
Sladden, 1999 ^323^ | Australia | 40–80 | 330 | 4 (3.98; 4.02)
Goepel, 2001 ^321^ | Germany | >40 | 211,648 | 14.3 (14.30; 14.30)
Ueda, 2000 ^172^ | Japan | 60–69 | 281 | 2.7 (2.68; 2.72)
Muscatello, 2001 ^160^ | Australia | 60–69 | 232 | 18 (17.95; 18.05)
Diokno, 1990 ^319^ | USA | 60–69 | 489 | 6.7 (6.68; 6.72)
Engstrom, 2003 ^125^ | UK | 60–69 | 465 | 9 (8.97; 9.03)
Lee, 1998 ^322^ | Korea | 60–69 | 181 | 14.9 (14.85; 14.95)
Bortolotti, 2000 ^165^ | Italy | >50 | 2,721 | 20 (19.98; 20.02)
Roberts, 1998 ^311^ | USA | >50 | 775 | 10.8 (10.78; 10.82)
Lee, 1998 ^322^ | Korea | >50 | 519 | 14.2 (14.17; 14.23)
Jitapunkul, 1998 ^182^ | Thailand | >60 | 232 | 7.33 (7.30; 7.36)
Stewart, 2002 ^141^ | USA | 65–74 | 232 | 8.2 (8.16; 8.24)
Corcos, 2004 ^12^ | Canada | 65–74 | 151 | 21.5 (21.44; 21.56)
Diokno, 1990 ^319^ | USA | >60 | 802 | 6.6 (6.58; 6.62)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >60 | 2,080 | 2.5 (2.49; 2.51)
Umlauf, 1996 ^195^ | USA | 52–99 | 1,490 | 10.6 (10.58; 10.62)
Tseng, 2000 ^171^ | Taiwan | >65 | 248 | 5.6 (5.57; 5.63)
Damian, 1998 ^176^ | Spain | >65 | 589 | 7.6 (7.58; 7.62)
Ju, 1991 ^205^ | Singapore | >65 | 435 | 0.5 (0.49; 0.51)
Maral, 2001 ^159^ | Turkey | >65 | 61 | 9.7 (9.63; 9.77)
Nuotio, 2002 ^148^ | Finland | 60–89 | 524 | 5.3 (5.28; 5.32)
Diokno, 1990 ^319^ | USA | 70–79 | 229 | 7.4 (7.37; 7.43)
Nuotio, 2002 ^148^ | Finland | 70–79 | 171 | 21.1 (21.04; 21.16)
Ueda, 2000 ^172^ | Japan | >70 | 160 | 3.4 (3.37; 3.43)
Muscatello, 2001 ^160^ | Australia | >70 | 232 | 17 (16.95; 17.05)
Engstrom, 2003 ^125^ | UK | 70–80 | 348 | 15 (14.96; 15.04)
Koyama, 1998 ^177^ | Japan | >60 | 856 | 3.7 (3.69; 3.71)
Lee, 1998 ^322^ | Korea | >70 | 106 | 23.5 (23.42; 23.58)
Nuotio, 2003 ^136^ | Finland | >70 | 171 | 17 (16.94; 17.06)
Stewart, 2002 ^141^ | USA | >75 | 128 | 12.8 (12.74; 12.86)
Corcos, 2004 ^12^ | Canada | >75 | 90 | 29.5 (29.41; 29.59)
Nuotio, 2002 ^148^ | Finland | 70–98 | 171 | 28.9 (28.83; 28.97)
Diokno, 1990 ^319^ | USA | >80 | 85 | 3.5 (3.46; 3.54)
Nuotio, 2002 ^148^ | Finland | 80–98 | 171 | 34.3 (34.23; 34.37)
Homma, 2005 ^113^ | Japan | 40–100 | 2,100 | 6 (5.99; 6.01)
Other type of UI
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | <39 | 2,933 | 1.5 (1.50; 1.50)
| Canada, Germany, Italy, Sweden, and the UK | >18 | 8,207 | 2.9 (2.90; 2.90)
| Canada, Germany, Italy, Sweden, and the UK | 40–59 | 3,033 | 3 (2.99; 3.01)
Diokno, 2007 ^89^ | USA | 18–97 | 21,590 | 1.2 (1.20; 1.20)
Koskimaki, 1998 ^178^ | Finland | 50–70 | 2,128 | 10 (9.99; 10.01)
Diokno, 1990 ^319^ | USA | 60–69 | 489 | 4.7 (4.68; 4.72)
Roberts, 1998 ^311^ | USA | >50 | 775 | 8.3 (8.28; 8.32)
Diokno, 1990 ^319^ | USA | >60 | 802 | 5.4 (5.38; 5.42)
Irwin, 2006 ^96^ | Canada, Germany, Italy, Sweden, and the UK | >60 | 1,981 | 5.2 (5.19; 5.21)
Damian, 1998 ^176^ | Spain | >65 | 589 | 3.1 (3.09; 3.11)
Diokno, 1990 ^319^ | USA | 70–79 | 229 | 5.2 (5.17; 5.23)
Koyama, 1998 ^177^ | Japan | >60 | 856 | 1.6 (1.59; 1.61)
Diokno, 1990 ^319^ | USA | >80 | 85 | 9.4 (9.34; 9.46)

Table F3 Prevalence of UI in American males by type and time period of involuntary loss of urine (the results from individual studies)

Author | Time Involuntary Leakage of Urine Reported (months) | Sample Size | Prevalence (%) 95%CI
Total UI
Median age of sample: 19–44 years
Diokno, 2007 ^89^ | 1 | 3,177 | 7.25 (7.24; 7.26)
| 1 | 4,295 | 7.17 (7.16; 7.18)
Smoger, 2000 ^169^ | 12 | 67 | 25.40 (25.30; 25.50)
Lagace, 1993 ^200^ | 12 | 922 | 11.30 (11.28; 11.32)
Median age of sample: 45–64 years
Diokno, 2007 ^89^ | 1 | 4,510 | 10.98 (10.97; 10.99)
Umlauf, 1996 ^195^ | 1 | 223 | 20.00 (19.95; 20.05)
Diokno, 2007 ^89^ | 1 | 3,113 | 15.58 (15.57; 15.59)
Smoger, 2000 ^169^ | 12 | 165 | 30.90 (30.83; 30.97)
Roberts, 19983 ^11^ | 12 | 225 | 16.90 (16.85; 16.95)
Smoger, 2000 ^169^ | 12 | 137 | 31.40 (31.32; 31.48)
Roberts, 1998 ^183^ | 12 | 2,150 | 17.30 (17.28; 17.32)
Smoger, 2000 ^169^ | 12 | 809 | 32.30 (32.27; 32.33)
Roberts, 1998 ^311^ | 12 | 766 | 26.40 (26.37; 26.43)
| 12 | 270 | 23.70 (23.65; 23.75)
Diokno, 1990 ^314^ | 6 days/12 | 489 | 18.20 (18.17; 18.23)
Stothers, 2005 ^116^ | ever | 5,037,678 | 11.00 (11.00; 11.00)
Temml, 2005 ^310^ | ND | 1199 | 1.80 (1.79; 1.81)
Median age of sample: ≥65 years
Diokno, 2007 ^89^ | 1 | 2,260 | 23.82 (23.80; 23.84)
Umlauf, 1996 ^195^ | 1 | 724 | 26.00 (25.97; 26.03)
Umlauf, 1996 ^195^ | 1 | 1,490 | 29.00 (28.98; 29.02)
| 1 | 452 | 38.00 (37.96; 38.04)
Smoger, 2000 ^169^ | 12 | 237 | 36.30 (36.24; 36.36)
Herzog, 1990 ^41^ | 12 | 802 | 18.80 (18.77; 18.83)
Roberts, 1998 ^311^ | 12 | 217 | 35.90 (35.84; 35.96)
Smoger, 2000 ^169^ | 12 | 178 | 33.20 (33.13; 33.27)
Langa, 2002 ^82^ | 12 | 2,812 | 13.00 (12.99; 13.01)
Diokno, 1990 ^314^ | 6 days/12 | 802 | 18.80 (18.77; 18.83)
Diokno, 1991 ^317^ | 6 days/12 | 655 | 20.20 (20.17; 20.23)
Diokno, 1990 ^314^ | 6 days/12 | 229 | 18.80 (18.75; 18.85)
Stothers, 2005 ^116^ | ever | 4,731,187 | 11.00 (11.00; 11.00)
| | 3,320,840 | 19.00 (19.00; 19.00)
| | 18,231,934 | 17.00 (17.00; 17.00)
| | 2,748,396 | 27.00 (27.00; 27.00)
Kutner, 1994 ^197^ | ND | 113 | 4.50 (4.46; 4.54)
Adelmann, 2004 ^50^ | ND | 163 | 25.80 (25.730; 25.87)
| | 22 | 13.60 (13.47; 13.73)
Median age of sample: ≥80 years
Diokno, 2007 ^89^ | 1 | 1,386 | 30.19 (30.17; 30.21)
Umlauf, 1996 ^195^ | 1 | 51 | 31.00 (30.88; 31.12)
| 1 | 3 | 66.00 (65.65; 66.35)
Roberts, 1998 ^311^ | 12 | 54 | 40.70 (40.57; 40.83)
Diokno, 1990 ^314^ | 12 | 85 | 22.40 (22.31; 22.49)
Smoger, 2000 ^169^ | 12 | 25 | 20.00 (19.85; 20.15)
Brandeis, 1997 ^186^ | 2 episodes/week | 474 | 24.10 (24.06; 24.14)
Stothers, 2005 ^116^ | ever | 1,478,414 | 27.00 (27.00; 27.00)
| | 915,419 | 31.00 (31.00; 31.00)
Boyington, 2007 ^43^ | ever | 22,539 | 72.20 (72.19; 72.21)
Temml, 2005 ^310^ | ND | 106 | 5.70 (5.66; 5.74)
Mixed UI
Median age of sample: 45–64 years
Diokno, 2007 ^89^ | 1 | 21,590 | 1.80 (1.80; 1.80)
Diokno, 1990 ^314^ | 6 days/12 | 489 | 5.30 (5.28; 5.32)
Median age of sample: ≥65 years
Diokno, 1990 ^314^ | 6 days/12 | 802 | 5.50 (5.48; 5.52)
| 6 days/12 | 229 | 4.40 (4.37; 4.43)
Umlauf, 1996 ^195^ | 1 | 1,490 | 13.10 (13.08; 13.12)
Roberts, 1998 ^183^ | 12 | 775 | 6.70 (6.68; 6.72)
Median age of sample: ≥80 years
Diokno, 1990 ^314^ | 6 days/12 | 85 | 9.40 (9.34; 9.46)
Stress UI
Median age of sample: 45–64 years
Diokno, 2007 ^89^ | 1 | 21,590 | 2.40 (2.40; 2.40)
Diokno, 1990 ^314^ | 12 | 489 | 1.40 (1.39; 1.41)
Muller, 2005 ^320^ | ND | 1,001 | 2.00 (1.99; 2.01)
Median age of sample: ≥65 years
Diokno, 1990 ^314^ | 6 days/12 | 802 | 1.40 (1.39; 1.41)
| 6 days/12 | 229 | 1.70 (1.68; 1.72)
Umlauf, 1996 ^195^ | 1 | 1,490 | 0.50 (0.50; 0.50)
Roberts, 1998 ^183^ | 12 | 775 | 0.90 (0.89; 0.91)
Median age of sample: ≥80 years
Diokno, 1990 ^314^ | 6 days/12 | 85 | 0.00 (0.00; 0.00)
Urge UI
Median age of sample: 45–64 years
Diokno, 1990 ^314^ | 6 days/12 | 489 | 6.70 (6.68; 6.72)
Diokno, 2007 ^89^ | 1 | 21,590 | 4.30 (4.30; 4.30)
Stewart, 2003 ^141^ | ND | 2,469 | 2.60 (2.59; 2.61)
Median age of sample: ≥65 years
Diokno, 1990 ^314^ | 6 days/12 | 802 | 6.60 (6.58; 6.62)
| 6 days/12 | 229 | 7.40 (7.37; 7.43)
Umlauf, 1996 ^195^ | 1 | 1,490 | 10.60 (10.58; 10.62)
Roberts, 1998 ^183^ | 12 | 775 | 10.80 (10.78; 10.82)
Stewart, 2003 ^141^ | ND | 232 | 8.20 (8.16; 8.24)
| ND | 128 | 12.80 (12.74; 12.86)
Median age of sample: ≥80 years
Diokno, 1990 ^314^ | 6 days/12 | 85 | 3.50 (3.46; 3.54)

Table F4 Prevalence of UI by severity in age groups of the American men (the results from individual studies)

Author | Time Involuntary Leakage of Urine Reported (months) | Frequency | Amount | Age | Sample Size | Prevalence (%) 95%CI
Median age: 19–44 years
Smoger, 2000 ^169^ | 12 | <1/month | | <40 | 67 | 11.90 (11.82; 11.98)
Lagace, 1993 ^200^ | 12 | <Once/month | Loss of a few drops | >20 | 922 | 2.30 (2.29; 2.31)
| | <Once/month | Wet outerwear | >20 | 922 | 0.30 (0.30; 0.30)
| | <Once/month | Wet underwear | >20 | 922 | 1.00 (0.99; 1.01)
Smoger, 2000 ^169^ | 12 | About 1/month | | <40 | 67 | 1.50 (1.47; 1.53)
Lagace, 1993 ^200^ | 12 | Monthly | Loss of a few drops | >20 | 922 | 2.10 (2.09; 2.11)
| | Monthly | Wet outerwear | >20 | 922 | 0.20 (0.20; 0.20)
| | Monthly | Wet underwear | >20 | 922 | 5.00 (4.99; 5.01)
| | Monthly | Wet underwear | >20 | 922 | 0.50 (0.50; 0.50)
Smoger, 2000 ^169^ | 12 | <1/week | | <40 | 67 | 1.50 (1.47; 1.53)(
| | About 1/week | | <40 | 67 | 1.50 (1.47; 1.53)
Lagace, 1993 ^200^ | 12 | Weekly | Loss of a few drops | >20 | 922 | 0.90 (0.89; 0.91)
| | Weekly | Wet outerwear | >20 | 922 | 0.20 (0.20; 0.20)
| | Weekly | Wet underwear | >20 | 922 | 0.80 (0.79; 0.81)
Smoger, 2000 ^169^ | 12 | Almost every day | | <40 | 67 | 9.00 (8.93; 9.07)
Lagace, 1993 ^200^ | 12 | Daily | Loss of a few drops | >20 | 922 | 0.80 (0.79; 0.81)
| | Daily | Wet outerwear | >20 | 922 | 0.80 (0.79; 0.81)
| | Daily | Wet underwear | >20 | 922 | 1.50 (1.49; 1.51)
Smoger, 2000 ^169^ | 12 | | Wet my underwear | <40 | 67 | 9.00 (8.93; 9.07)
| | | Wet outer clothing | <40 | 67 | 3.00 (2.96; 3.04)
Roberts, 1998 ^183^ | 12 | | Wet underclothing | 40–79 | 2,150 | 10.80 (10.79; 10.81)
Median age: 45–64 years
Smoger, 2000 ^169^ | 12 | <1/month | | 41–50 | 165 | 6.10 (6.06; 6.14)
| | <1/month | | 51–60 | 137 | 6.60 (6.56; 6.64)
| | <1/month | | 25–93 | 809 | 6.60 (6.58; 6.62)
| | About 1/month | | 41–50 | 165 | 4.80 (4.77; 4.83)
| | About 1/month | | 51–60 | 137 | 5.10 (5.06; 5.14)
| | About 1/month | | 25–93 | 809 | 4.70 (4.69; 4.71)
Stothers, 2005 ^116^ | Ever | Few times/month | | 60–64 | 5,037,678 | 1.00 (1.00; 1.00)
| | Few times/year | | 60–64 | 5,037,678 | 2.00 (2.00; 2.00)
Smoger, 2000 ^169^ | 12 | <1/week | | 41–50 | 165 | 4.20 (4.17; 4.23)
| | <1/week | | 51–60 | 137 | 2.90 (2.87; 2.93)
| | <1/week | | 25–93 | 809 | 3.30 (3.29; 3.31)
| | About 1/week | | 41–50 | 165 | 7.30 (7.26; 7.34)
| | About 1/week | | 51–60 | 137 | 8.00 (7.96; 8.04)
| | About 1/week | | 25–93 | 809 | 6.80 (6.78; 6.82)
Stothers, 2005 ^116^ | Ever | Few times/week | | 60–64 | 5,037,678 | 4.00 (4.00; 4.00)
Smoger, 2000 ^169^ | 12 | Almost every day | | 41–50 | 165 | 4.80 (4.77; 4.83)
| | Almost every day | | 51–60 | 137 | 4.40 (4.37; 4.43)
| | Almost every day | | 25–93 | 809 | 7.00 (6.98; 7.02)
Stothers, 2005 ^116^ | Ever | Daily | | 60–64 | 50,37,678 | 4.00 (4.00; 4.00)
| | Do not know | | 60–64 | 50,37,678 | 0.00 (0.00; 0.00)
Roberts, 1998 ^183^ | 12 | | A few drops | 40–79 | 2,150 | 4.20 (4.19; 4.21)
Smoger, 2000 ^169^ | 12 | | Few Drops | <40 | 67 | 13.40 (13.32; 13.48)
| | | Few Drops | 41–50 | 165 | 13.90 (13.85; 13.95)
| | | Few Drops | 51–60 | 137 | 21.20 (21.13; 21.27)
| | | Few Drops | 25–93 | 809 | 19.50 (19.47; 19.53)
| | | Wet my underwear | 41–50 | 165 | 10.90 (10.85; 10.95)
| | | Wet my underwear | 51–60 | 137 | 8.00 (7.96; 8.04)
| | | Wet my underwear | 25–93 | 809 | 7.80 (7.78; 7.82)
Roberts, 1998 ^183^ | 12 | | Wet outer | 40–79 | 2,150 | 2.20 (2.19; 2.21)
| | | clothes/floor
Smoger, 2000 ^169^ | 12 | | Wet outer clothing | 41–50 | 165 | 4.20 (4.17; 4.23)
| | | Wet outer clothing | 51–60 | 137 | 0.70 (0.69; 0.71)
| | | Wet outer clothing | 25–93 | 809 | 2.20 (2.19; 2.21)
| | | Wet the floor | <40 | 67 | 0.00 (0.00; 0.00)
| | | Wet the floor | 41–50 | 165 | 0.00 (0.00; 0.00)
| | | Wet the floor | 51–60 | 137 | 0.00 (0.00; 0.00)
| | | Wet the floor | 25–93 | 809 | 0.70 (0.69; 0.71)
Median age: ≥65 years
Smoger, 2000 ^169^ | 12 | <1/month | | 61–70 | 237 | 7.60 (7.57; 7.63)
| | <1/month | | 71–80 | 178 | 4.50 (4.47; 4.53)
| | About 1/month | | 61–70 | 237 | 5.90 (5.87; 5.93)
| | About 1/month | | 71–80 | 178 | 3.40 (3.37; 3.43)
Stothers, 2005 ^116^ | Ever | Few times/month | | 65–69 | 4,731,187 | 2.00 (2.00; 2.00)
| | Few times/month | | 70–74 | 3,320,840 | 4.00 (4.00; 4.00)
| | Few times/month | | 75–79 | 2,748,396 | 6.00 (6.00; 6.00)
| | Few times/month | | >65 | 18,231,934 | 3.00 (3.00; 3.00)
| | Few times/month | | >65 | 14,790,935 | 3.00 (3.00; 3.00)
| | Few times/month | | >65 | 1,436,582 | 2.00 (2.00; 2.00)
| | Few times/month | | >65 | 559,680 | 1.00 (1.00; 1.00)
| | Few times/month | | >65 | 429,299 | 10.00 (10.00; 10.00)
| | Few times/month | | >65 | 1,015,438 | 8.00 (8.00; 8.00)
| | Few times/year | | 65–69 | 4,731,187 | 2.00 (2.00; 2.00)
| | Few times/year | | 70–74 | 3,320,840 | 3.00 (3.00; 3.00)
| | Few times/year | | 75–79 | 2,748,396 | 3.00 (3.00; 3.00)
| | Few times/year | | >65 | 18,231,934 | 3.00 (3.00; 3.00)
| | Few times/year | | >65 | 14,790,935 | 3.00 (3.00; 3.00)
| | Few times/year | | >65 | 1,436,582 | 2.00 (2.00; 2.00)
| | Few times/year | | >65 | 559,680 | 1.00 (1.00; 1.00)
| | Few times/year | | >65 | 429,299 | 0.00 (0.00; 0.00)
| | Few times/year | | >65 | 1,015,438 | 1.00 (1.00; 1.00)
Smoger, 2000 ^169^ | 12 | <1/week | | 61–70 | 237 | 3.80 (3.78; 3.82)
| | <1/week | | 71–80 | 178 | 2.80 (2.78; 2.82)
| | About 1/week | | 61–70 | 237 | 5.50 (5.47; 5.53)
| | About 1/week | | 71–80 | 178 | 9.60 (9.56; 9.64)
Stothers, 2005 ^116^ | Ever | Few times/week | | 65–69 | 4,731,187 | 3.00 (3.00; 3.00)
| | Few times/week | | 70–74 | 3,320,840 | 3.00 (3.00; 3.00)
| | Few times/week | | 75–79 | 2,748,396 | 4.00 (4.00; 4.00)
| | Few times/week | | >65 | 18,231,934 | 4.00 (4.00; 4.00)
| | Few times/week | | >65 | 14,790,935 | 3.00 (3.00; 3.00)
| | Few times/week | | >65 | 1,436,582 | 7.00 (7.00; 7.00)
| | Few times/week | | >65 | 559,680 | 3.00 (3.00; 3.00)
| | Few times/week | | >65 | 429,299 | 15.00 (15.00; 15.00)
| | Few times/week | | >65 | 1,015,438 | 6.00 (6.00; 6.00)
Smoger, 2000 ^169^ | 12 | Almost every day | | 61–70 | 237 | 8.90 (8.86; 8.94)
| | Almost every day | | 71–80 | 178 | 8.40 (8.36; 8.44)
Stothers, 2005 ^116^ | Ever | Daily | | 65–69 | 4,731,187 | 4.00 (4.00; 4.00)
| | Daily | | 70–74 | 3,320,840 | 9.00 (9.00; 9.00)
| | Daily | | 75–79 | 2,748,396 | 14.00 (14.00; 14.00)
| | Daily | | >65 | 18,231,934 | 7.00 (7.00; 7.00)
| | Daily | | >65 | 14,790,935 | 7.00 (7.00; 7.00)
| | Daily | | >65 | 1,436,582 | 8.00 (8.00; 8.00)
| | Daily | | >65 | 559,680 | 9.00 (9.00; 9.00)
| | Daily | | >65 | 429,299 | 9.00 (9.00; 9.00)
| | Daily | | >65 | 1,015,438 | 7.00 (7.00; 7.00)
| | Do not know | | 65–69 | 4,731,187 | 0.00 (0.00; 0.00)
| | Do not know | | 70–74 | 3,320,840 | 0.10 (0.10; 0.10)
| | Do not know | | 75–79 | 2,748,396 | 0.30 (0.30; 0.30)
| | Do not know | | >65 | 18,231,934 | 0.20 (0.20; 0.20)
| | Do not know | | >65 | 14,790,935 | 0.20 (0.20; 0.20)
| | Do not know | | >65 | 1,436,582 | 0.60 (0.60; 0.60)
| | Do not know | | >65 | 559,680 | 0.30 (0.30; 0.30)
| | Do not know | | >65 | 429,299 | 0.00 (0.00; 0.00)
| | Do not know | | >65 | 1,015,438 | 0.00 (0.00; 0.00)
Smoger, 2000 ^169^ | 12 | | Few Drops | 61–70 | 237 | 24.50 (24.45; 24.55)
| | | Few Drops | 71–80 | 178 | 21.30 (21.24; 21.36)
Roberts, 1998 ^183^ | 12 | | Mild | >50 | 775 | 20.10 (20.07; 20.13)
Smoger, 2000 ^169^ | 12 | | Wet my underwear | 61–70 | 237 | 6.30 (6.27; 6.33)
| | | Wet my underwear | 71–80 | 178 | 5.60 (5.57; 5.63)
| | | Wet outer clothing | 61–70 | 237 | 2.10 (2.08; 2.12)
| | | Wet outer clothing | 71–80 | 178 | 1.70 (1.68; 1.72)
| | | Wet the floor | 61–70 | 237 | 1.30 (1.29; 1.31)
| | | Wet the floor | 71–80 | 178 | 1.10 (1.08; 1.12)
Median age: ≥80 years
Smoger, 2000 ^169^ | 12 | <1/month | | 80–93 | 25 | 0.00 (0.00; 0.00)
| | About 1/month | | 80–93 | 25 | 8.00 (7.90; 8.10)
Stothers, 2005 ^116^ | Ever | Few times/month | | 80–84 | 1,478,414 | 4.00 (4.00; 4.00)
| Ever | Few times/month | | >85 | 915,419 | 8.00 (8.00; 8.00)
| | Few times/year | | 80–84 | 1,478,414 | 4.00 (4.00; 4.00)
| | Few times/year | | >85 | 915,419 | 3.00 (3.00; 3.00)
Smoger, 2000 ^169^ | 12 | <1/week | | 80–93 | 25 | 4.00 (3.93; 4.07)
| | About 1/week | | 80–93 | 25 | 4.00 (3.93; 4.07)
Stothers, 2005 ^116^ | Ever | Few times/week | | 80–84 | 1,478,414 | 9.00 (9.00; 9.00)
| | Few times/week | | >85 | 915,419 | 5.00 (5.00; 5.00)
| 12 | Almost every day | | 80–93 | 25 | 4.00 (3.93; 4.07)
| Ever | Daily | | 80–84 | 1,478,414 | 9.00 (9.00; 9.00)
| | Daily | | >85 | 915,419 | 15.00 (15.00; 15.00)
| | Do not know | | 80–84 | 1,478,414 | 1.00 (1.00; 1.00)
| | Do not know | | >85 | 915,419 | 2.00 (2.00; 2.00)
Smoger, 2000 ^169^ | 12 | | Few Drops | 80–93 | 25 | 4.00 (3.93; 4.07)
| | | Wet my underwear | 80–93 | 25 | 12.00 (11.88; 12.12)
| | | Wet outer clothing | 80–93 | 25 | 0.00 (0.00; 0.00)
| | | Wet the floor | 80–93 | 25 | 4.00 (3.93; 4.07)

Table F5 Severity of FI in LTC facilities

Author | Population Subgroup | Severity of Fecal incontinence | Prevalence(%)
Sample
Brocklehurst, 1998 ^324^ | Nursing homes | Fecal incontinence, <1/week | 23.0
N = 497 | Nursing homes, residents with arthritis/fracture femur | Fecal incontinence, >1/week | 16.0
| Nursing homes, residents with congestive heart failure/Ischemic heart disease | Fecal incontinence, >1/week | 5.0
| Nursing homes, residents with dementia | Fecal incontinence, >1/week | 45.0
| Nursing homes, frail | Fecal incontinence, >1/week | 16.0
| Nursing homes, residents with stroke | Fecal incontinence, >1/week | 25.0
| Nursing homes | Fecal incontinence, 1–3 days/week | 13.0
| Nursing homes | Fecal incontinence, 4–7 days/week | 16.0
Bharucha, 2005 ^241^ | Nursing homes, women | Moderate fecal incontinence | 8.1
N = 2,800
Haas, 2005 ^325^ | Residents with spinal cord injury | Spontaneous bowel evacuation | 12.4
N = 837

Table F6 Prevalence of FI in community dwelling women by type of incontinence

Author | Prevalence (%) | 95% CI
Flatus
Chaliha, 1999 ^326^ | 0.5 | 0.19; 1.59
N = 549
Alnaif, 2001 ^327^ | 34.9 | 29.05; 41.31
N = 229
N = 298, <60 years old | 5.3 | 3.33; 8.54
Faltin 2001 ^328^ | 4.4 | 3.26; 5.83
N = 984, total
Hojberg, 2003 ^329^ | 7.1 | 6.5; 7.65
N = 7,557
Walter, 2002 ^330^ | 9.9 | 7.70; 12.59
N = 577
Eva, 2003 ^127^ | 42.0 | 37.83; 46.21
N = 529
Boreham, 2005 ^331^ | 25.6
N = 457
Ballester, 2005 ^332^ | 7.0
N = 115
Bradley, 2006 ^64^ | 33.0
N = 297
Gordon, 1999 ^333^ | 14.0
N = 283
Roche, 2002 ^334^ | 6.7 | 4.67; 9.51
N = 418
MacLennan, 2000 ^84^ | 10.9 | 9.41; 12.52
N = 1,546
Lam, 1999 ^335^ | 7.5 | 5.22; 10.72
N = 359
Kjolhede, 1997 ^336^ excluded in endnote | 0.0 | 0; 8.03
N = 44
Lopes, 1997 ^337^ | 8.7 | 4.67; 15.78
N = 103
Combined urge and passive fecal incontinence
Bharucha, 2005 ^241^ (N = 2,800) | 1.0
Liquid feces
Boreham, 2005 ^331^ | 12.9
N = 457
Ballester, 2005 ^332^ | 5.2
N = 115
Bharucha, 2005 ^241^ | 5.3
N = 2,800
Bradley, 2006 ^64^ | 11.1
N = 297
Gordon, 1999 ^333^ | 6.0
N = 283
Melville, 2005 ^338^ | 3.4
N = 3,444
Alnaif, 2001 ^327^ | 2.6 | 1.21; 5.6
N = 229
Chaliha, 1999 ^326^ | 0.2 | 0.03; 1.02
N = 549
Hojberg, 2003 ^329^ | 2.5 | 2.14; 2.85
N = 7,557
Eva, 2003 ^127^ | 29.0 | 25.57; 32.59
N = 639
Walter, 2002 ^330^ | 1.0 | 0.48; 2.25
N = 577
Kalantar, 2002 ^339^ | 8.8 | 6.26; 12.2
N = 353
Roche, 2002 ^334^ | 4.8 | 3.12; 7.27
N = 418
Kjølhede, 1997 ^336^ | 0.0 | 0; 8.03
N = 44
Passive fecal incontinence
Bharucha, 2005 ^241^ | 0.8
N = 2,800
Solid and liquid feces
Melville, 2005 ^338^ | 2.2
N = 3,444
Roberts, 1999 ^340^ | 15.2 | 12.85; 21.87
N = 762
Eva, 2003 ^127^ | 9.0 | 7.02; 11.36
N = 670
Lopes, 1997 ^337^ | 7.8 | 3.9; 14.58
N = 103
Kok, 1992 ^202^ | 7.2 | 5.42; 9.50
N = 625
Diokno, 1990 ^314^ | 8.3 | 7.62; 11.28
N = 969
Walter, 2002 ^330^ | 0.7 | 0.20; 2.62
N = 274
Thomas, 1984 ^341^ | 2.9 | 2.16; 3.83
N = 1,562
Verhagen, 2001 ^342^ | 8.0 | 7.11; 8.95
N = 3,345
Edwards, 2001 ^277^ | 4.0 | 2.92; 4.73
N = 1,695
Wetle, 1995 ^343^ | 7.8 | 6.78; 8.95
N = 2,360
O'Keefe, 1995 ^212^ | 8.1 | 5.34; 12.03
N = 260
Solid feces
Boreham, 2005 ^331^ | 13.1
N = 457
Bharucha, 2005 ^241^ | 5.6
N = 2,800
Bradley, 2006 ^64^ | 1.7
N = 297
Gordon, 1999 ^333^ | 9.0
N = 283
Melville, 2005 ^338^ | 1.7
N = 3,444
Alnaif, 2001 ^327^ | 0.0 | 0; 2
N = 229
Chaliha, 1999 ^326^ | 0.7 | 0.03; 1.02
N = 549
Hojberg, 2003 ^329^ | 1.4 | 1.13; 1.65
N = 7,557
Eva, 2003 ^127^ | 9.0 | 5.39; 9.29
N = 639
Walter, 2002 ^330^ | 0.0 | 0; 0.66
N = 577
Kalantar, 2002 ^339^ | 1.1 | 0.4; 2.9
N = 353
Okonkwo, 2002 ^280^ | 2.2 | 1.76; 2.67
N = 3,963
Roche, 2002 ^334^ | 1.7 | 0.81; 3.42
N = 418
Rizk, 2001 ^344^ | 5.6 | 3.79; 8.07
N = 450
Kjolhede, 1997 ^336^ | 0.0 | 0; 8.03
N = 44
Solid or liquid feces
Alnaif, 2001 ^327^ | 2.6 | 1.21; 5.6
N = 229
Faltin, 2001 ^328^ | 1.4 | 0.52; 3.40
N = 298
Hojberg, 2003 ^329^ | 2.7 | 2.36; 3.09
N = 7,557
Enck, 1991 ^219^ | 1.4 | 0.24; 7.36
N = 73
Thomas, 1984 ^341^ | 1.0 | 0.79; 1.30
N = 6,205
Kalantar, 2002 ^339^ | 11.6 | 8.68; 15.38
N = 353
Okonkwo, 2002 ^280^ | 4.8 | 4.22; 5.56
N = 3,963
Perry, 2002 ^279^ | 2.7 | 2.3; 3.16
N = 5,483
Roche, 2002 ^334^ | 6.5 | 4.48; 9.23
N = 418
Manning, 2001 ^345^ | 9.1 | 5.72; 15.25
N = 148
Rizk, 2001 ^344^ | 11.3 | 8.73; 14.60
N = 450
MacLennan, 2000 ^84^ | 3.5 | 2.69; 4.54
N = 1,546
Mann, 2000 ^346^ | 8.5 | 4.79; 14.52
N = 130
Soligo, 2000 ^347^ | 4.9 | 2.13; 11.07
N = 101
Lam, 1999 ^335^ | 5.6 | 3.64; 8.45
N = 359
Kjolhede, 1997 ^336^ | 0.0 | 0; 8.03
N = 44
Drossman, 1993 ^257^ | 0.9 | 0.61; 1.32
N = 2,791
Bharucha, 2005 ^241^ | 7.1
N = 2,800
Bradley, 2005 ^64^ | 20.3
N = 297
Urge fecal incontinence
Bharucha, 2005 ^241^ ( N = 2,800) | 6.2
Vaginal or perineal splinting to defecate by age categories
Bradley, 2005 ^64^ | <64 years = 4.0
N = 297 | >72 years = 8.1
| 64–67 years = 3.0
| 68–72 years = 5.1

Table F7 Prevalence of FI in community dwelling women by severity of incontinence

Author | Severity | Prevalence (%) | 95% CI
Sample
Ballester, 2005 ^332^ | Fecal incontinence, <1 episode/month | 6.1
N = 115 | Fecal incontinence, >1/month | 0.9 | 0.39; 5.9
Talley, 1992 ^214^ | Fecal incontinence more than once a week | 3.1 | 2.9; 10.6
N = 328 | Wear a pad for fecal incontinence | 6.7
Bharucha, 2005 ^241^ | Fecal incontinence, <1/month | 9.6
N = 2,800
Melville, 2005 ^338^ | Fecal incontinence, >1/month | 4.6
N = 3,444 | Fecal incontinence, >1/week | 2.7
Bharucha, 2005 ^241^ | Fecal incontinence, >1/week | 1.6
N = 2,800 | Fecal incontinence, 1/month | 4.3
| Fecal incontinence, 1/week | 2.2
Bradley, 2005 ^64^ | Fecal incontinence, 1–3 times monthly | 4.0
N = 297 | Fecal incontinence, 1–6 times weekly | 3.4
| Fecal incontinence, daily | 1.4
Bharucha, 2005 ^241^ | Fecal incontinence, daily | 0.4
N = 2,800
Bradley, 2005 ^64^ | Fecal incontinence, ever | 34.0
N = 297
Bharucha, 2005 ^241^ | Fecal incontinence, large to change clothes | 1.3
N = 2,800
Bradley, 2005 ^64^ | Fecal incontinence, less than once a month | 25.3
N = 297
Bharucha, 2005 ^241^ | Fecal incontinence, moderate | 5.9
N = 2,800 | Fecal incontinence, underwear stains only | 10.7
Ballester, 2005 ^332^ | Liquid feces, <1 episode/month, age 20–64 | 3.5
N = 115 | Liquid feces, >1 episode/month, age 20–64 | 1.7
Bharucha, 2005 ^241^ | Moderate fecal incontinence, age 20–29 | 0.3
N = 2,800 | Moderate fecal incontinence, age 30–39 | 0.7
| Moderate fecal incontinence, age 40–49 | 1.3
| Moderate fecal incontinence, age 50–59 | 1.8
| Moderate fecal incontinence, age 60–69 | 2.0
| Moderate fecal incontinence, age 70–79 | 1.9 | 31.95; 44.43
Alnaif 2001 ^327^ | Underwear staining | 38.0 | 0.24; 7.36
N = 229
Enck 1991 ^219^ | Underwear staining | 1.4 | 12.35; 17.08
N = 73
Walter 2002 ^330^ | Underwear staining | 14.5 | 0.10; 1.32
N = 852
Chaliha, 1999 ^326^ | Underwear staining | 0.4 | 6.83; 8.22
N = 549
Perry, 2002 ^279^ | Underwear staining | 7.5
N = 5,483
Ballester, 2005 ^332^ | Wear pad | 1.7
N = 115

Table F8 Prevalence of FI in community dwelling adults (men and women)

Author | Age Categories | Prevalence (%) | 95% CI
Sample
Combined urinary and fecal incontinence
Teunissen, 2004 ^119^ | 60–64 | 2.0 | 1.4; 2.8
N = 4,650 | 65–69 | 3.0 | 2.1; 4.3
| 70–74 | 4.0 | 2.8; 5.6
| 75–79 | 6.0 | 4.2; 8.4
Brittain, 2006 ^348^ | | 0.9
N = 39,519
Anal incontinence
Nelson, 1995 ^272^ | <65 | 1.6
N = 6,959 | >65 | 0.7
| | 2.2
Damon, 2006 ^349^ | | 5.1 | 3.6; 7.0
N = 706
Brittain, 2006 ^348^ | | 2.9
N = 39,519
Johanson, 1996 ^350^ | <30 | 12.3
N = 881 | >18 | 18.4
| >70 | 19.4
Teunissen, 2004 ^119^ | 60–64 | 5.0 | 4.0; 6.3
N = 4,650 | 65–69 | 5.0 | 3.9; 6.4
| 70–74 | 8.0 | 6.3; 10.1
Teunissen, 2004 ^119^ | 75–79 | 8.0 | 6.1; 10.5
N = 4,650
Liquid feces
Giebel, 1998 ^273^ | >18 years | 6.7
N = 500
Soiling underwear
Giebel, 1998 ^273^ | >18 years | 3.1
N = 500
Solid feces
Giebel, 1998 ^273^ | >18 years | 4.8
N = 500
Bytzer, 2001 ^351^ | 18–101 | 0.8
N = 8,185
Solid or liquid feces
Campbell, 1985 ^352^ | >65 | 3.1
N = 559
Bytzer, 2001 ^351^ | 18–101 | 3.8
N = 8185
Giebel, 1998 ^273^ | >18 years | 6.7
N = 500
Flatus
Giebel, 1998 ^273^ | >18 years | 5.5
N = 500

Table F9 Prevalence of FI in community dwelling adults (men and women) by severity

Author | Definition | Age Categories | Prevalence (%)
Sample
Johanson, 1996 ^350^ | Fecal incontinence, <1/month | | 7.1
N = 881 | Fecal incontinence, daily | | 2.7
| Fecal incontinence, weekly | | 4.5
| Wear pad | | 22.7
Talley, 1992 ^214^ | Fecal incontinence, >1/week | >65 | 3.7
N = 328 | Wear pad | >65 | 7.0
Brittain, 2006 ^348^ | Fecal incontinence, furnishing or bedding | 1,483 after stroke | 11.0
N = 39,519 | Fecal incontinence, outer clothing | 1,483 after stroke | 6.0
| Major fecal incontinence | | 1.5
Lynch, 2001 ^278^ | Flatus, <1/day | <60 | 6.1
N = 717 | Flatus, <1/month | <60 | 28.7
| Flatus, <1/week | <60 | 27.8
| Flatus, >1/day | <60 | 1.4
| Lifestyle alteration, <1/day | <60 | 1.4
| Lifestyle alteration, <1/month | <60 | 4.6
| Lifestyle alteration, <1/week | <60 | 2.1
| Liquid, <1/day | <60 | 0.7
| Liquid, <1/month | <60 | 7.4
| Liquid, <1/week | <60 | 4.2
| Liquid, >1/day | <60 | 0.4
| Wear pad, <1/month | <60 | 1.3
| Wear pad, <1/week | <60 | 0.3
| Wear pad, <1/day | <60 | 0.1
| Solid, <1/day | <60 | 1.1
| Solid, <1/month | <60 | 5.4
| Solid, <1/week | <60 | 2.8
| Solid, >1/day | <60 | 0.4
Damon, 2006 ^349^ | Flatus, <1/month | | 13.2
N = 706 | Flatus, <1/week | | 7.9
| Flatus, <1/week | | 6.6
| Liquid feces, <1/month | | 8.3
| Liquid feces, <1/week | | 0.5
| Liquid feces, <1/week | | 0.6
| Sold feces, <1/month | | 0.9
| Sold feces, <1/week | | 0.4
| Sold feces, <1/week | | 0.1
| Wear pad, <1 month | | 1.3
| Wear pad, <1 week | | 0.8
| Wear pad, <1 week | | 0.2
Giebel, 1998 ^273^ | Frequent stools after meal | >18 years | 20.1
N = 500 | Frequent stools due to stress | >18 years | 44.8
| Frequent flatus during micturition | >18 years | 56.5

Table F10 Prevalence of FI in community dwelling adults by race

Author | Race | Definition | Prevalence (%)
Sample
Men and women
Nelson, 1995 ^272^ | White | Anal incontinence | 2.1
N = 6,959
Men
Goode, 2005 ^248^ | African-American | Fecal incontinence | 13.5
N = 1,000 | White | Fecal incontinence | 11.2
Women
Goode, 2005 ^248^ | African-American | Fecal incontinence | 9.2
N = 1,000 | White | Fecal incontinence | 14
Huang, 2006 ^70^ | Asians | Anal incontinence | 21.2
N = 345 | Asians | Combined urinary and anal incontinence | 10.7
| Asians | Fecal incontinence | 4.1
| Asians | Flatus | 19.4
Huang, 2006 ^70^ | White | Anal incontinence | 28.6
N = 1,003 | White | Combined urinary and anal incontinence | 19.9
| White | Fecal incontinence | 6.8
| White | Flatus | 25.5
Jackson, 1997 ^303^ | African-American | Fecal incontinence | 18.8
N = 16
Jackson, 1997 ^303^ | White | Fecal incontinence | 21.2
N = 184
Melville, 2005 ^338^ | Non-white race | Fecal incontinence | 0.8
N = 3,444

Table F11 Association between age and UI in women

Author, Sample | Age | Definition of Severity | Age | Odds Ratio (95%CI)
Incident UI, Total
Jackson, 2004 ^22^ | 70–79 | At least weekly | 75–79 vs. 70–74 | 1.5 (0.98; 2.3)
N = 1,584
Ostbye, 2004 ^28^ | >65 | In the last 12 months | 75–84 vs. <75 | 1.11 (0.9; 1.37)
N = 5,322 | | In the last 12 months | 85+ vs. <75 | 1.17 (0.81; 1.69)
Prevalent UI
Brown, 1999 ^353^ | Mean: 67 | Within the past week | Age (per 5 y) | 1.1 (1.02; 1.18)
N = 2,763 | (SD: 7)
Prevalent UI, Stress
Brown, 1999 ^353^ | Mean: 67 | Within the past week | Age (per 5 y) | 0.93 (0.85; 1.03)
N = 2,763 | (SD: 7)
McGrother, 2006 ^6^ | >40 | Monthly or more | Age (10-year increase) | 0.9 (0.7; 1)
N = 12,570
Moller, 2000, ^354^ | 40–60 | Sometime or more often | 45 vs. <45 | 1.4 (0.9; 2)
N = 3,208 | | | 50s. <45 | 1.6 (1.1; 2.2)
| | | 55s. <45 | 1.9 (1.3; 2.7)
| | | 60s. <45 | 1.6 (1.1; 2.3)
Chen, 2003 ^123^ | >20 | Within the past 2 weeks | > 65 vs. <65 | 0.8 (0.3; 1.8)
N = 1,247
Rohr, 2005 ^107^ | >45 | Within the past month | 60–80 vs. <60 | 1.33 (1.09; 1.62)
N = 5,795 | | Within the past month | >80 vs. <60 | 2.39 (1.97; 2.9)
Prevalent UI, Total
Holtedahl, 1998 ^355^ | 50–74 | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Age (per year increase) | 0.98
N = 507 | | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Age (per year increase) | 0.97
Nygaard, 2003 ^79^ | 50–69 | Mild-moderate incontinence - Incontinence on 15 or fewer days in the last month In the last 12 months, have you lost any amount of urine beyond your control | Age(per year increase) | 0.97 (0.95; 0.99)
N = 5,701 | | Severe incontinence-incontinence on more than 15 days in the last month | Age(per year increase) | 0.77 (0.29; 2.03)
Waetjen, 2007 ^49^ | 42–52 | Frequency: at least monthly | Age(per year increase) | 1.03 (0.99; 1.06)
N = 3,302 | | Frequency: >weekly/daily | Age(per year increase) | 1.06 (1.01; 1.12)
Hvidman, 2003 ^356^ | 20–59 | Within the past seven days | Age per year | 1.06 (1.03; 1.08)
Brown, 2006 ^95^ | 69–101 | Daily UI | Per 5 year | 1.3 (1.2; 1.5)
N = 7,949
Brown, 2006 ^95^ | >20 | Weekly urinary incontinence | Age (per 5 years)in diabetics | 1.19 (0.96; 1.48)
N = 1,461
Melville, 2005 ^112^ | 30–90 | Frequency: at least monthly. Severe: Sandvik severity index score of 6–8 | Age, per decade | 1.4 (1.1; 1.2)
N = 3,596 | | | Age, per decade | 1.2 (1.1; 1.4)
Van Oyen, 2002 ^157^ | ≥15 | At least once a week, at least once a month, less than once a month | 25–34 vs. 15–24 | 1.87 (0.51; 6.85)
N = 3,804 | | | 35–44 vs. 15–24 | 2.09 (0.58; 7.5)
Danforth, 2006 ^68^ | 25–54 | Occasional: 1–3 times a month. | 40–44 vs. <40 | 1.2 (1.1; 1.3)
N = 83,355 | | Frequent: At least weekly. | 40–44 vs. <40 | 1.2 (1.1; 1.2)
| | Severe: Wet underwear. | 40–44 vs. <40 | 1.3 (1.2; 1.4)
Maclennan, 2000 ^84^ | 15–97 | Within the past year | 35–54 vs. 15–34 | 2.1 (1.5; 3)
N = 3,010
Danforth, 2006 ^68^ | 25–54 | Occasional: 1–3 times a month. | 45–49 vs. <40 | 1.3 (1.2; 1.4)
N = 83,355 | | Frequent: At least weekly. | 45–49 vs. <40 | 1.3 (1.3; 1.4)
| | Severe: Wet underwear. | 45–49 vs. <40 | 1.7 (1.6; 1.8)
Van Oyen, 2002 ^157^ | ≥15 | At least once a week, at least once a month, less than once a month | 45–54 vs. 15–24 | 3.03 (0.88; 10.49)
N = 3,804
Fitzgerald, 2002 ^81^ | 40 | Leaked urine at least monthly | >50 years | 3.09 Sign
N = 265
Sampselle, 2002 ^151^ | 42–52 | Frequency and volume: | 48–52 y vs. 42–47 y | 1.18 (1; 1.38)
N = 3,302 | | frequency score is multiplied by volume score
Grodstein, 2003 ^129^ | ≥20 years | Occasional leaking - leaking one to three times per month | 50–55 vs. < 50 years | 1.07 (0.97; 1.17)
N = 27,936 | | Occasional leaking - leaking one to three times per month at least enough to wet underwear | 50–55 vs. < 50 years | 1.01 (0.9; 1.13)
| | Frequent leaking is defined as at least once per week | 50–55 vs. < 50 years | 0.96 (0.88; 1.06)
Danforth, 2006 ^68^ | 25–54 | Occasional: 1–3 times a month. | 50–54 vs. <40 | 1.4 (1.3; 1.5)
N = 83,355 | | Frequent: At least weekly. | 50–54 vs. <40 | 1.4 (1.3; 1.4)
| | Severe: Wet underwear. | 50–54 vs. <40 | 1.8 (1.7; 2)
Grodstein, 2003 ^129^ | ≥20 years | Frequent leaking - at least once per week at least enough to wet underwear | 50–55 vs. < 50 | 0.95 (0.85; 1.05)
N = 27,936
Maclennan, 2000 ^84^ | 15–97 | Within the past year | ≥ 55 vs. 15–34 | 3.1 (2.1; 4.5)
N = 3,010
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, stress UI, urge UI | 50–59 vs. 41–49 years | 3.7 (1.7; 8.2)
N = 262
Grodstein, 2003 ^129^ | ≥20 years | Occasional leaking -leaking one to three times per month | 56–60 vs. < 50 | 1.1 (0.99; 1.21)
N = 27,936 | | Frequent leaking - at least once per week at least enough to wet underwear | 56–60 vs. < 50 | 1.07 (0.95; 1.21)
| | Occasional leaking - leaking one to three times per month at least enough to wet underwear | 56–60 vs. < 50 | 1.07 (0.94; 1.22)
| | Frequent leaking - at least once per week | 56–60 vs. < 50 | 1.08 (0.98; 1.2)
Van Oyen, 2002 ^157^ | ≥15 | At least once a week, at least once a month, less than once a month | 55–64 vs. 15–24 | 4.85 (1.41; 16.67)
N = 3,804
Fornel, 2004 ^208^ | 40 yr and 60 yr | Leakage weekly or more often | 60 cohort vs. 40 cohort | 1.9 (1.2; 3.2)
N = 1,336
Jackson, 2006, ^100^ | 55–75 | Severe: Sandvik score of 6–8 over the past year | 60–64 vs. 55–59 | 1.4 (0.7; 2.7)
N = 1,017
Grodstein, 2003 ^129^ | ≥20 years | Occasional leaking - leaking one to three times per month | 61–65 vs. <50 | 1.2 (1.08; 1.32)
N = 27,936 | | Occasional leaking - leaking one to three times per month at least enough to wet underwear | 61–65 vs. <50 years | 1.22 (1.07; 1.39)
| | Frequent leaking - at least once per week | 61–65 vs. <50 years | 1.22 (1.1; 1.35)
| | Frequent leaking -at least once per week at least enough to wet underwear | 61–65 vs. <50 years | 1.24 (1.1; 1.4)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | 60–64 vs. 55–59 | 0.8 (0.6; 1.2)
N = 1,017
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, Stress UI, urge UI | 60–69 vs. 41–49 | 1.9 (0.7; 5.2)
N = 262
Grodstein, 2003 ^129^ | ≥20 years | Frequent leaking is defined as at least once per week at least enough to wet underwear | 66–70 vs. <50 years | 1.56 (1.39; 1.76)
N = 27,936 | | Frequent leaking is defined as at least once per week | 66–70 vs. < 50 years | 1.49 (1.34; 1.64)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | 65–69 vs.55–59 | 1 (0.7; 1.5)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | 65–69 vs. 55–59 | 1.7 (0.9; 3.2)
Grodstein, 2003 ^129^ | ≥20 years | Occasional leaking is defined as leaking one to three times per month | 66–70 vs. < 50 years | 1.28 (1.16; 1.42)
N = 27,936 | | Occasional leaking is defined as leaking one to three times per month at least enough to wet underwear | 66–70 vs. < 0 years | 1.37 (1.2; 1.56)
Van Oyen, 2002 ^157^ | ≥15 | At least once a week, at least once a month, less than once a month | 65–74 vs. 15–24 | 7.22 (2.15; 24.21)
N = 3,804
Maggi, 2001 ^158^ | >65 | Rarely, 1 to 2 times per month, ≥1/week, or every day | >70 years | 1.49 (1.11; 2.02)
N = 1,531
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, stress UI, urge UI | >70 vs. 41–49 years | 2.9 (1.1; 7.6)
N = 262
Grodstein, 2003 ^129^ | ≥20 years | Occasional leaking is defined as leaking one to three times per month | >70 vs. < 50 years | 1.45 (1.29; 1.63)
N = 27,936 | | Occasional leaking is defined as leaking one to three times per month at least enough to wet underwear | >70 vs. < 50 years | 1.56 (1.35; 1.81)
| | Frequent leaking is defined as at least once per week | >70 vs. < 50 years | 1.67 (1.49; 1.87)
| | Ft least once per week at least enough to wet underwear | >70 vs. < 50 years | 1.81 (1.59; 2.07)
Rohr, 2005 ^107^ | >45 | Within the past month | 60–80 vs. <60 | 1.54 (1.29; 1.84)
N = 5,795
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | 70–76 vs. 55–59 | 1 (0.7; 1.4)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | 70–76 vs. 55–59 | 1.4 (0.8; 2.4)
Van Oyen, 2002 ^157^ | ≥15 | At least once a week, at least once a month, less than once a month | 75+ vs. 15–24 | 6.89 (2; 23.71)
N = 3,804
Ostbye, 2004 ^28^ | >65 | In the last 12 months, have you lost any amount of urine beyond your control | 75–84 vs. <75 | 1.47 (1.2; 1.79)
N = 5,322
Landi, 2003 ^131^ | 79.5+-9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | 75–84 vs. 65–74 | 0.91 (0.63; 1.32)
N = 3,194
Fultz, 1999 ^357^ | >70 | Mild=0–6 days/month Have you ever lost urine when you were not able to get to the toilet on time?, have you ever lost urine when you are asleep?, have you ever lost urine when you laugh, cough or sneeze?, and if they stated they leaked urine at least monthly | >80 years | 0.77 (0.61; 0.97)
N = 3,991 | | Moderate=7–20days/month Have you ever lost urine when you were not able to get to the toilet on time?, have you ever lost urine when you are asleep?, have you ever lost urine when you laugh, cough or sneeze?, and if they stated they leaked urine at least monthly | >80 years | 1.34 (0.89; 2.02)
| | Severe ≥21 days/month Have you ever lost urine when you were not able to get to the toilet on time?, have you ever lost urine when you are asleep?, have you ever lost urine when you laugh, cough or sneeze?, and if they stated they leaked urine ≥1/month | >80 years | 1.46 (1.09; 1.94)
Rohr, 2005 ^107^ | >45 | Within the past month | >80 vs. <60 | 2.89 (2.42; 3.45)
N = 5,795
Ostbye, 2004 ^28^ | >65 | In the last 12 months, have you lost any amount of urine beyond your control | 85+ vs. <75 | 1.78 (1.35; 2.37)
N = 5,322
Landi, 2003 ^131^ | 79.5+-9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | >85 vs. 65–74 | 1.61 (1.15; 2.2 6)
N = 3,194
Prevalent UI, Urge
Brown, 1999 ^353^ | Mean: 67 | Within the past week | Age (per 5 y) | 1.19 (1.09; 1.31)
N = 2,763 | (SD: 7)
Huang, 2006 ^70^ | 40–69 | At least weekly incontinence to recall the number of episodes in the past 7 days | Age (per 10 y) | 1.79 (1.34; 2.4)
N = 345 Asian women
Moller, 2000 ^354^ | 40–60 | Sometime or more often | 45s. <45 | 1.6 (0.9; 2.7)
N = 3,208 | | Sometime or more often | 50s. <45 | 2.1 (1.2; 3.5)
Ueda, 2000 ^172^ | 40–75 | 1 = Never, 2 = Seldom, 3 = Sometimes, 4 = Very Often | 50–59 vs. 40–49 | 0.739 (0.506; 1.079)
N = 968
Moller, 2000 ^354^ | 40–60 | Sometime or more often | 55s. <45 | 2.4 (1.4; 3.9)
N = 3,208 | | Sometime or more often | 60s. <45 | 2.7 (1.6; 4.5)
Ueda, 2000 ^172^ | 40–75 | 1 = Never, 2 = Seldom, 3 = Sometimes, 4 = Very Often | 60–69 vs. 40–49 | 0.468 (0.319; 0.685)
N = 968 | | 1 = Never, 2 = Seldom, 3 = Sometimes, 4 = Very Often | 70+ vs. 40–49 | 0.426 (0.259; 0.7)
Rohr, 2005 ^107^ | >45 | Within the past month | 60–80 vs. <60 | 1.84 (1.45; 2.34)
N = 5,795
Jackson, 2004 ^21^ | 70–79 | Within the past week | 75–79 (y) vs. 70–74 | 1.6 (1.11; 2.3)
N = 1,584
Rohr, 2005 ^107^ | >45 | Within the past month | >80 vs. <60 | 4.01 (3.17; 5.08)
N = 5,795

Bold- significant results at 95%confidence level

Table F12 Association between race and prevalent UI in women

Author, Sample | Age | Definition of UI | Race vs. Caucasian | Odds Ratio (95%CI)
Mixed UI
Brown, 1999 ^353^ | Mean: 67 ±7 | UI within the past week | White vs. other | 2.14 (1.48; 3.08)
N – 2,763
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | African American | 0.35 (0.23; 0.53)
N = 3,302 | | | Chinese | 0.38 (0.21; 0.7)
| | | Japanese | 3.19 (0.55; 18.29)
| | | Hispanic | 0.12 (0.05; 0.27)
Sampselle, 2002 ^151^ | 42–52 | Frequency score is multiplied by volume score | African American | 0.88 (0.67; 1.16)
N = 3,302 | | | Chinese | 0.7 (0.4; 1.21)
| | | Hispanic | 0.65 (0.34; 1.28)
| | | Japanese | 1.13 (0.68; 1.88)
Stress UI
Brown, 1999 ^353^ | Mean: 67 ±7 | UI within the past week | White vs. other | 2.84 (1.6; 5.05)
N - 2,763
Jackson, 2004 ^21^ | 70–79 | UI within the past week | White vs. other | 4.11 (2.53; 6.67)
N = 1,584
Thom, 2006 ^99^ | 40–69 | UI at least weekly | Hispanic | 1.42 (0.98; 2.06)
N = 2,109 | | | African American | 0.36 (0.23; 0.57)
| | | Asian-American | 0.54 (0.34; 0.86)
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | African American | 0.26 (0.19; 0.36)
N = 3,302 | | | Chinese | 0.47 (0.31; 0.7)
| | | Japanese | 0.77 (0.55; 1.12)
| | | Hispanic | 0.27 (0.17; 0.42)
Urge UI
Brown, 1999 ^353^ | Mean: 67 (SD: 7) | UI within the past week | White vs. other | 1.26 (0.83; 1.91)
N - 2,763
Jackson, 2004 ^21^ | 70–79 | UI within the past week | White vs. other | 3.09 (1.99; 4.78)
N = 1,584
Thom, 2006 ^99^ | 40–69 | UI at least weekly | Hispanic | 1.37 (0.85; 2.19)
N = 2,109 | | | African American | 1.19 (0.79; 1.81)
| | | Asian-American | 0.86 (0.52; 1.43)
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | African American | 0.98 (0.65; 1.48)
N = 3,302 | | | Chinese | 0.43 (0.22; 0.84)
| | | Japanese | 0.37 (0.18; 0.74)
| | | Hispanic | 0.1 (0.03; 0.34)

Table F13 Association between body mass index and UI in females

Author, Sample | Age | Definition of Severity | Strata of Risk Factors with Cut Offs | Odds Ratio (95%CI)
Incident UI
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | BMI per 1 unit increase | 1.09 (1.04; 1.13)
N = 3,302
Dallosso, 2003 ^14^ | >40 | UI at least several times a month | Underweight vs. normal weight | 0.69 (0.38; 1.3)
N = 6,424 | | | Overweight vs. normal weight | 1.3 (0.94; 1.7)
| | | Obese vs. normal weight | 1.7 (1.2; 2.5)
| | UI at least monthly | BMI per 1 unit increase | 1.06 (1.03; 1.1)
| | UI >weekly/daily | BMI per 1 unit increase | 1.12 (1.06; 1.19)
Prevalent Urge UI
Mommsen, 1994 ^198^ | 30–59 | UI in the past year | BMI per 1 unit increase | 1.08 (1.05; 1.11)
N = 2,589
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | BMI per 1 unit increase | 1.03 (1; 1.06)
N = 3,302
Brown, 1999 ^353^ | Mean: 67 (SD: 7) | UI within the past week | BMI per 5 unit increase | 1.09 (0.99; 1.22)
N = 2,763
Kuh, 1999Kuh, 1999 ^179^ | 48 | UI at least two hourly during the day and at least twice a night | BMI per 5 unit increase | 1.2 (0.98; 1.3)
N = 1,333
Huang, 2006 ^70^ | 40–69 | UI at least weekly | BMI 25 kg/m2 in Asian women | 3.35 (1.22; 9.18)
N = 345
Rohr, 2005 ^107^ | >45 | UI in the past month | BMI 25–30 vs. <25 | 1.4 (1.19; 1.64)
N = 5,795
Huang, 2006 ^70^ | 40–69 | UI at least weekly | BMI >25 | 1.71 (1.04; 2.82)
N = 345 Asian women
Rohr, 2005 ^107^ | >45 | UI in the past month | BMI>30 vs. <25 | 1.84 (1.41; 2.39)
N = 5,795
Stress UI
Persson, 2000 ^358^ | | Ever had incontinence surgery | BMI <19.8 | 1 (1; 1)
N = 1,492 | | | BMI <19.8 | 1.41 (1.16; 1.71)
| | | BMI 19.8–26 | 0.8 (0.6; 1.06)
| | | BMI 19.8–26 | 1.34 (1.02; 1.76)
| | | BMI >26 | 1 (1; 1)
| | | BMI >26 | 1 (1; 1)
Chen, 2003 ^123^ | >20 | UI in the past week | BMI ≥75th percentile with symptoms of uterovaginal prolapse vs. <75th percentile and no prolapse | 33 (12.5; 87.1)
N = 1,247
Total UI
Brown, 2006 ^95^ | >20 | UI at least weekly | BMI (kg/m2)in diabetics | 1.05 (0.97; 1.14)
N = 1,461
Moghaddas, 2005 ^359^ | 50–64 | Ever UI | BMI <20 vs. 20–25;Women with depression | 0.58 (0.4; 0.86)
N = 6,642 | | Ever UI | BMI >25 vs. 20–25;Women with depression | 1.56 (1.32; 1.85)
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, stress UI, urge UI | BMI >30 vs. 25 | 1.5 (0.5; 4.6)
N = 262 | | >1 symptom: nocturia, urgency, stress UI, urge UI | BMI 25 vs. <19 | 0.3 (0.1; 0.8)
| | >1 symptom: nocturia, urgency, stress UI, urge UI | BMI> 29 vs. 25–29 | 1.2 (0.6; 2.4)
Holtedahl, 1998 ^355^ | 50–74 | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | BMI per 1 unit increase | 1.06
N = 507 | | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | BMI per 1 unit increase | 1.09
Van Oyen, 2002 ^157^ | ≥15 | At least once a week, at least once a month, less than once a month | BMI > 30 vs. 20–25 | 2.23 (1.51; 3.29)
N = 3,804
Sampselle, 2002 ^151^ | 42–52 | Frequency score is multiplied by volume score | BMI per 1 unit increase | 1.05 (1.04; 1.07)
N = 3,302 | | | BMI per 1 unit increase | 1.04 (1.03; 1.06)
Fultz, 1999 ^357^ | >70 | Moderate=7–20 days/month | BMI >28.1 vs. <22.1 | 2.37 (1.48; 3.8)
N = 3,991
Danforth, 2006 ^68^ | 25–54 | Severe: Wet underwear. | BMI < 22 vs. 22–24 | 0.7 (0.7; 0.8)
N = 83,355 | | Severe: Wet underwear. | BMI ≥ 30 vs. 22–24 | 3.1 (2.9; 3.3)
| | Severe: Wet underwear. | BMI 25–29 vs. 22–24 | 1.5 (1.4; 1.6)
Jackson, 2006 ^100^ | 55–75 | Severe: Sandvik score of 6–8 over the past year | BMI > 29 vs. <25 | 1.5 (0.9; 2.4)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | BMI 25–29 vs. <25 | 1.5 (0.9; 2.4)
Fultz, 1999 ^357^ | >70 | Severe ≥21 days/month | BMI >28.1 vs. <22.1 | 1.65 (1.31; 2.1)
N = 3,991
Fitzgerald, 2002 ^81^ | 40 | UI at least monthly | BMI ≥ 25 vs. <25 | 1.8 (Significance)
N = 265

Bold- significant results at 95%confidence level

Table F14 Association between behavioral and environmental factors and UI in women

Author, Sample | Age | Definition UI | Risk Factors | Odds Ratio (95%CI)
Incident UI, Physical activity, Total UI
Ostbye, 2004 ^28^ | >65 | UI in the last 12 months | Exercise | 1.04 (0.85; 1.29)
N = 5,322
Danforth, 2007 ^44^ | 54–79 | UI in the last 12 months | Physical activity (MET-h/wk) 2 vs.1 quantile | 1.04 (0.92; 1.18)
N = 1,566 | | | Physical activity (MET-h/wk) 3 vs.1 quantile | 0.9 (0.79; 1.02)
| | | Physical activity (MET-h/wk) 4 vs.1 quantile | 0.85 (0.75; 0.98)
| | | Physical activity (MET-h/wk) 5 vs.1 quantile | 0.81 (0.71; 0.93)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 1.01 (0.88; 1.14)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.91 (0.8; 1.04)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.9 (0.78; 1.04)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.74 (0.63; 0.88)
Incident UI, Physical activity, Stress
Danforth, 2007 ^44^ | 54–79 | UI in the last 12 months | Physical activity (MET-h/wk) 2 vs.1 quantile | 1.22 (0.99; 1.5)
N = 1,566 | | | Physical activity (MET-h/wk) 3 vs.1 quantile | 0.91 (0.73; 1.13)
| | | Physical activity (MET-h/wk) 4 vs.1 quantile | 0.86 (0.68; 1.08)
| | | Physical activity (MET-h/wk) 5 vs.1 quantile | 0.71 (0.56; 0.91)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 1.21 (0.97; 1.5)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 1.18 (0.95; 1.48)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 1.01 (0.79; 1.28)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.76 (0.57; 1.02)
Incident UI, Physical activity, Urge
Danforth, 2007 ^44^ | 54–79 | UI in the last 12 months | Physical activity (MET-h/wk) 2 vs.1 quantile | 0.8 (0.57; 1.13)
N = 1,566 | | | Physical activity (MET-h/wk) 3 vs.1 quantile | 0.74 (0.52; 1.04)
| | | Physical activity (MET-h/wk) 4 vs.1 quantile | 0.94 (0.68; 1.31)
| | | Physical activity (MET-h/wk) 5 vs.1 quantile | 0.96 (0.69; 1.34)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.81 (0.58; 1.13)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.65 (0.45; 0.93)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.95 (0.68; 1.33)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.76 (0.51; 1.14)
Incident UI, Physical activity, Mixed
Danforth, 2007 ^44^ | 54–79 | UI in the last 12 months | Physical activity (MET-h/wk) 2 vs.1 quantile | 0.96 (0.73; 1.27)
N = 1,566 | | | Physical activity (MET-h/wk) 3 vs.1 quantile | 0.84 (0.63; 1.12)
| | | Physical activity (MET-h/wk) 4 vs.1 quantile | 0.81 (0.6; 1.1)
| | | Physical activity (MET-h/wk) 5 vs.1 quantile | 0.76 (0.56; 1.04)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 1.06 (0.8; 1.41)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.83 (0.61; 1.12)
| | | Walking (MET-h/wk) 2 vs.1 quantile | 0.87 (0.64; 1.2)
Incident UI, Social support
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | Social support <25th percentile vs. >25th percentile | 1.42 (0.96; 2.09)
N = 3,302
Prevalent UI, Education
Fultz, 1999 ^357^ | >70 | Mild=0–6 days/month | Education (>12 years) | 1.34 (1.05; 1.7)
N = 3,991 | | Moderate=7–20days/month | Education (>12 years) | 1.06 (0.66; 1.7)
| | Severe ≥21 days/month | Education (>12 years) | 0.94 (0.68; 1.3)
Kuh, 1999Kuh, 1999 ^179^ | 48 | Stress ≥2/hour during the day and ≥2/night | Educational level (o-no education, 4- degree level) | 1.3 (1.2; 1.5)
N = 1,333 | | ≥2/hour during the day and ≥2/night | Educational level (o-no education, 4- degree level) | 0.86 (0.72; 1)
Bortolotti, 2000 ^165^ | ≥40 | Within the past year | Secondary/higher vs. none/primary | 0.7 (0.5; 1)
N = 2,767
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Secondary/higher vs. primary | 1.12 (0.91; 1.38)
N = 1,262
Nygaard, 2003 ^79^ | 50–69 | Mild-moderate incontinence - ≤15 days/last month | Education | 1.3 (1.04; 1.63)
N = 5,701 | | Severe incontinence- >15 days in the last month | Education | NS
Moghaddas, 2005 ^359^ | 50–64 | Any leakage | Education (university) | 2.04 (1.8; 2.32)
N = 6,642 | | Any leakage | Education (university);Women with depression | 1.98 (1.68; 2.35)
| | Any leakage | Education (university) | 2.12 (1.75; 2.56)
Waetjen, 2007 ^49^ | 42–52 | Urge UI at least monthly | High school or less vs. college or mor | 0.72 (0.51; 1.03)
N = 3,302
Sampselle, 2002 ^151^ | 42–52 | Frequency score is multiplied by volume score | College and above vs. below college level | 1.31 (1.1; 1.57)
N = 3,302
Prevalent UI, Employment type
Chen, 2003 ^123^ | >20 | Stress UI in the past 2 weeks | Labor work vs. non-labor work | 0.5 (0.2; 1)
N = 1,247
Prevalent UI, Environmental barriers
Landi, 2003Landi, 2003 #937} | 79.5+9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | Yes | 2.95 (1.75; 4.96)
N = 3,194
Prevalent UI, Marital status
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, stress UI, urge UI | Widowed/divorce/separated vs. Married with partner | 0.7 (0.3; 1.5)
N = 262 | | >1 symptom: nocturia, urgency, stress UI, urge UI | Never married vs. Married with partner | 2.5 (1; 6.5)
| | >1 symptom: nocturia, urgency, stress UI, urge UI | No private health insurance vs. yes | 2.6 (1.4; 5)
Prevalent UI, Physical activity
Brown, 1996 ^194^ | 69–101 | Daily | Physical exercise (prior year) vs. no regular exercise | 0.9 (0.7; 1.1)
N = 7,949
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Physical activity1+ per week | 0.97 (0.78; 1.2)
N = 1,262
Van Oyen, 2002 ^157^ | ≥15 | ≥1/week, ≥1/month, <1/month | Physical activity, sport < 4 hrs/wk or light activities | 1.19 (0.04; 2.35)
N = 3,804 | | | Physical activity Sedentary activities | 1.85 (0.69; 3)
| | | Physical activity sport <4 hrs/wk or light activities | 3.98 (0.96; 16.51)
| | | Physical activity Sedentary activities | 4.49 (1.07; 18.83)
Ostbye, 2004 ^28^ | >65 | In the last 12 months, have you lost any amount of urine beyond your control | Exercise | 0.96 (0.8; 1.16)
N = 5,322
Prevalent UI, Social support
Nuotio, 2003 ^136^ | >70 | Stress UI, ever | Low social activity ( < 3 events or visits vs. 3+) | 0.6 (0.3; 1.4)
N = 227
Waetjen, 2007 ^49^ | 42–52 | Frequency: at least monthly | Social support < 25th percentile vs. >25th percentile | 1.39 (1.06; 1.81)
N = 3,302 | | Frequency: >weekly/daily | Social support < 25th percentile vs. >25th percentile | 1.87 (1.32; 2.66)
| | Mixed UI at least monthly | Social support <25th percentile vs. >25th percentile | 1.95 (1.32; 2.89)
Prevalent UI, Psychological Stress
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Feeling stressed | 1.3 (1.06; 1.59)
N = 1.262
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, stress UI, urge UI | High stress vs. low | 2.7 (1.1; 7)
N = 262
Prevalent UI, Body composition
Waetjen, 2007 ^49^ | 42–52 | Mixed UI, at least monthly | Waist circumference, cm per cm increase | 1.04 (1.01; 1.07)
N = 3,302
Brown, 1999 ^353^ | Mean: 67 | Mixed UI in the past week | Waist/hip ratio (per 0.1 unit) | 1.09 (0.96; 1.23)
N = 2,763 | (SD: 7)
Waetjen, 2007 ^49^ | 42–52 | Stress UI at least monthly | Waist circumference, cm per cm increase | 1.04 (1.02; 1.06)
N = 3,302
Brown, 1999 ^353^ | Mean: 67 | Stress UI in the past week | Waist/hip ratio (per 0.1 unit) | 1.18 (1; 1.39)
N = 2,763 | (SD: 7)
Waetjen, 2007 ^49^ | 42–52 | Frequency: at least monthly | Waist circumference, cm per cm increase | 1.03 (1.01; 1.05)
N = 3,302 | | Frequency: >weekly/daily | Waist circumference, cm per cm increase | 1.05 (1.02; 1.07)
Brown, 1999 ^353^ | Mean: 67 | Total UI within the past week | Waist/hip ratio (per 0.1 unit) | 1.06 (0.91; 1.23)
N = 2,763 | (SD: 7)

Bold- significant results at 95% confidence level

Table F15 Association between dietary intake and UI in women

Author, Sample | Age | Definition of UI | Risk Factors | Odds Ratio 95%CI
Incident UI
Ostbye, 2004 ^28^ | >65 | UI in the last 12 months | Coffee drinker | 0.86 (0.69; 1.06)
N = 8,949)
Dallosso, 2003 ^14^ | >40 | Stress UI at least several times a month | Bread daily vs. less than daily | 0.76 (0.61; 0.96)
N = 6424 | | | Carbonated drinks 1/week vs. < 1 | 1.1 (0.8; 1.5)
| | | Carbonated drinks 2–6/week vs. <1 | 1.1 (0.81; 1.5)
| | | Carbonated drinks daily vs. < 1 | 1.6 (1.2; 2.2)
Prevalent UI
Brown, 1996 ^194^ | 69–101 | Daily UI | Alcohol use (drinks/wk per SD) | 0.9 (0.8; 1)
N= 7949
Fultz, 1999 ^357^ | >70 | UI at least monthly; mild = 0–6 days/month | Daily use of alcohol | 1.48 (0.96; 2.29)
N = 3991 | | UI at least monthly; moderate = 7–20days/month | | 1.6 (0.72; 3.57)
| | UI at least monthly; severe ≥21 days/month | | 0.87 (0.48; 1.59)
Schmidbauer, 2001 ^62^ | ≥20 | Leakage within the past 4 weeks | 1–6 drinks per week vs. 0 | 1.28 (0.94; 1.74)
N = 1262 | | | Daily alcohol vs. never | 1.83 (1.27; 2.63)
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, stress UI, urge UI | Current occasional alcohol drinker vs. non drinker | 0.8 (0.4; 1.8)
N = 262 | | | Current regular drinker vs. non drinker | 0.4 (0.2; 1)
Teleman, 2004 ^360^ | 50–59 | UI at least occasionally | Low alcohol consumption | 0.7 (0.6; 0.9)
N = 2682 | | | Moderate alcohol consumption | 0.6 (0.5; 0.9)
Bortolotti, 2000 ^165^ | ≥40 | UI in the last 12 months | Alcoholic drinks/week is 1–7 vs. 0 | 0.7 (0.4; 1)
N = 2767 | | | Alcoholic drinks/week is 8–14 vs. 0 | 1 (0.5; 1.7)
| | | Alcoholic drinks/week is 15–21 vs. 0 | 0.7 (0.3; 2.1)
| | | Alcoholic drinks/week is ≥22 vs. 0 | 0.5 (0.1; 2.2)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a wee | Alcohol (# glasses per week) 1–7 | 0.82 (0.6; 1.14)
N = 3804 | | | Alcohol (# glasses per week) 8–14 | 0.55 (0.29; 1.05)
| | | Alcohol (# glasses per week) 15–21 | 0.62 (0.23; 1.69)
| | | Alcohol (# glasses per week) ≥22 | 1.34 (0.55; 3.22)
Brown, 1996 ^194^ | 69–101 | Daily UI | Coffee drinker vs. non-coffee drinker | 0.9 (0.8; 1.1)
N = 7949
Bortolotti, 2000 ^165^ | ≥40 | UI in the last 12 months | Coffee cups/day 1 vs. 0 | 0.6 (0.4; 1.1)
N = 2767 | | | Coffee cups/day 2 vs. 0 | 0.5 (0.3; 1)
| | | Coffee cups/day ≥3 vs. 0 | 0.4 (0.3; 0.8)
Ostbye, 2004 ^165^ | >65 | UI in the last 12 months | Coffee Drinker | 1.23 (1.01; 1.51)
N = 5322

Bold -significant associations

Table F16 Association between smoking and UI in women

Author, Sample | Age | Definition UI | Smoking | Odds ratio (95%CI)
Mixed UI
Hannestad, 2003 ^361^ | ≥20 | Moderate UI daily leakage of drops | Cigarettes/day current, 1–19 vs. never | 1.1 (1; 1.3)
N = 27,936 | | | Cigarettes/day current, 20+ vs. cigarettes/day never | 1.6 (1.2; 2.1)
| | | Cigarettes/day former, >20 vs. never | 2.2 (1.7; 2.8)
| | | Cigarettes/day Former, 1–19 vs. never | 1.2 (1; 1.3)
| | | Pack years current, .15+ vs. never | 1.4 (1.2; 1.6)
| | | Pack years current, <15 vs. never | 1 (0.9; 1.2)
| | | Pack years Former, <15 vs. never | 1.1 (1; 1.3)
| | | Pack years former, 15+ vs. never | 1.6 (1.3; 2.1)
| | | Smoking Current vs. never | 1.2 (1; 1.3)
| | | Smoking Former vs. never | 1.2 (1.1; 1.4)
Stress UI
Hannestad, 2003 ^361^ | ≥20 | Moderate UI daily leakage of drops | Cigarettes/day current, 1–19 vs. never | 0.8 (0.7; 0.9)
N = 27,936 | | | Cigarettes/day current, 20+ vs. never | 1.2 (1; 1.5)
| | | Cigarettes/day former, >20 vs. never | 1.3 (1; 1.7)
| | | Cigarettes/day Former, 1–19 vs. never | 1.1 (1; 1.2)
| | | Pack years current, .15+ vs. never | 1 (0.9; 1.2)
| | | Pack years current, <15 vs. never | 0.7 (0.6; 0.8)
| | | Pack years Former, <15 vs. never | 1.1 (1; 1.2)
| | | Pack years former, 15+ vs. never | 1.3 (1.1; 1.6)
| | | Smoking Current vs. never | 0.8 (0.8; 0.9)
| | | Smoking Former vs. never | 1.1 (1; 1.2)
Total UI
Danforth, 2006 ^68^ | 25–54 | Occasional: 1–3 times a month. | Current vs. never | 0.9 (0.9; 1)
N = 83,355 | | Frequent: At least weekly. | Current vs. never | 1.2 (1.1; 1.3)
| | Severe: Wet underwear. | Current vs. never | 1.3 (1.3; 1.5)
| | Occasional: 1–3 times a month. | Former vs. never | 1 (1; 1.1)
| | Frequent: At least weekly. | Former vs. never | 1.1 (1.1; 1.2)
| | Severe: Wet underwear. | Former vs. never | 1.1 (1.1; 1.2)
Van Oyen, 2002 ^157^ | ≥15 | ≥1/week | <20 cig/day vs. never | 0.77 (0.46; 1.32)
N = 3,804 | | ≥1/week | ≥20 cig/day vs. never | 1.78 (1.05; 3.03)
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Cigarettes/day 1+ vs. 0 | 1.23 (0.75; 2.02)
N = 1,262
Bortolotti, 2000 ^165^ | ≥40 | Within the past year | Cigarettes/day >10–20 vs. 0 | 0.9 (0.5; 1.7)
N = 2,767 | | | Cigarettes/day >20 vs. 0 | 0.8 (0.4; 1.5)
| | | Cigarettes/day >5–10 vs. 0 | 0.9 (0.4; 2.1)
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Cigarettes/day 1–20 vs. 0 | 0.91 (0.69; 1.2)
N = 1,262
Bortolotti, 2000 ^165^ | ≥40 | Within the past year | Cigarettes/day1–5 vs. 0 | 0.9 (0.4; 2)
N = 2,767
Hannestad, 2003 ^361^ | ≥20 | Moderate = daily leakage of drops | Cigarettes/day current, 1–19 vs. never | 0.9 (0.9; 1)
N = 27,936 | | | Cigarettes/day current, 20+ vs. never | 1.3 (1.1; 1.6)
| | | Cigarettes/day former, 1–19 vs. never | 1.1 (1; 1.2)
Fultz, 1999 ^357^ | >70 | UI at least monthly | Current smoker | 0.65 (0.41; 1.04)
N = 3,991 | | Moderate UI: 7–20days/month | Current smoker | 1.12 (0.52; 2.41)
| | Severe UI >21 days/month | Current smoker | 1.21 (0.76; 1.91)
Bortolotti, 2000 ^165^ | ≥ 40 | UI within the past year | Current smokers vs. never smokers | 0.8 (0.5; 1.4)
N – 2,767
Schmidbauer, 2001 ^62^ | ≥20 | UI within the past 4 weeks | Current smokers vs. never smokers | 1 (0.77; 1.3)
N = 1,262
Swanson, 2005 ^106^ | 45–81 | UI within the past month | Ever smoked cigarettes | 1.7 (1; 2.7)
N = 606 | | | Ever smoked cigarettes | 1.5 (1; 2.1)
Bortolotti, 2000 ^165^ | ≥ 40 | Within the past year | Ex smokers vs. never smokers | 0.9 (0.5; 1.7)
N = 2,767
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Ex smokers vs. never smokers | 1.3 (1; 1.68)
N = 1,262
Hannestad, 2003 ^361^ | ≥20 | Moderate = daily leakage of drops | Cigarettes/day former, >20 vs. never | 1.7 (1.4; 2)
N = 27,936 | | | Pack years current, .15+ vs. never | 1.2 (1; 1.3)
| | | Pack years current, <15 vs. never | 0.9 (0.8; 1)
| | | Pack years Former, <15 vs. never | 1.1 (1; 1.2)
| | | Pack years former, 15+ vs. never | 1.5 (1.3; 1.7)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | Past smoker vs. never | 1.39 (0.98; 1.98)
N = 3,804
Ostbye, 2004 ^28^ | >65 | UI in the last 12 months | Smoked < 1 pack/days | 1.02 (0.82; 1.26)
N = 5,322 | | | Smoked < 1 pack/ days | 1.15 (0.91; 1.45)
| | | Smoked 1+ packs/ days | 1.41 (1.06; 1.87)
| | | Smoked 1+ packs/ days | 0.94 (0.67; 1.32)
Nygaard, 2003 ^79^ | 50–69 | UI 15 or fewer days in the last month | Smoking | NS
N = 5,701 | 50–69 | UI> 15 days in the last month | Smoking | 1.48 (1.08; 2.03)
Moghaddas, 2005 ^359^ | 50–64 | any leakage | Smoking (yes) | 0.85 (0.73; 1)
N = 6,642 | | | Smoking (yes) | 0.86 (0.67; 1.1)
| | | Smoking (yes);Women with depression | 0.85 (0.7; 1.04)
Hannestad, 2003 ^361^ | ≥20 | All: (Slight = drops of urine a few times a month, Moderate = daily leakage of drops, Severe = larger amounts at least once a week). | Smoking Current vs. never | 1 (0.9; 1)
N = 27,936 | | | Smoking Former vs. never | 1.1 (1.1; 1.3)
| | | Cigarettes/day current, 1–19 vs. never | 1.2 (1; 1.5)
| | | Cigarettes/day current, 20+ vs. never | 1.3 (0.8; 1.4)
| | | Cigarettes/day Former, 1–19 vs. never | 1.1 (0.9; 1.4)
| | | Former, >20 vs. never | 1.9 (1.2; 3.2)
| | | Pack years current, .15+vs. never | 1.2 (0.9; 1.6)
| | | Pack years current, <15 vs. never | 1.3 (1; 1.7)
| | | Pack years Former, <15 vs. never | 1.1 (0.9; 1.4)
| | | Pack years former, 15+ vs. never | 1.9 (1.3; 2.8)
| | | Smoking Current vs. never | 1.2 (1; 1.5)
| | | Smoking Former vs. never | 1.2 (1; 1.5)
Hannestad, 2003 ^361^ | ≥20 | Mixed UI:larger amounts at least once a week, 56 g/24 hours | Cigarettes/day current, 1–19 vs. never | 1.4 (1.1; 1.7)
N = 27,936 | | | Cigarettes/day current, 20+ vs. never | 2.4 (1.6; 3.6)
| | | Cigarettes/day former, >20 vs. never | 3.3 (2.2; 4.9)
| | | Cigarettes/day Smoking Former, 1–19 vs. never | 1.3 (1; 1.6)
| | | Pack years current, <15 vs. never | 1.1 (0.9; 1.5)
| | | Pack years current, 15+ vs. never | 1.9 (1.5; 2.4)
| | | Pack years Former, <15 vs. never | 1.3 (1; 1.6)
| | | Pack years former, 15+ vs. never | 2 (1.4; 2.8)
| | | Smoking Current vs. never | 1.5 (1.2; 1.8)
| | | Smoking Former vs. never | 1.5 (1.2; 1.8)
Hannestad, 2003 ^361^ | ≥20 | Stress UI: larger amounts at least once a week, 56 g/24 hours | Cigarettes/day current, 1–19 vs. never | 1.1 (0.8; 1.4)
N = 27,936 | | | Cigarettes/day current, 20+ vs. never | 1.8 (1.1; 2.9)
| | | Cigarettes/day former, >20 vs. never | 1.4 (0.7; 2.6)
| | | Cigarettes/day Former, 1–19 vs. never | 1.1 (0.8; 1.4)
| | | Pack years current, <15 vs. never | 1 (0.7; 1.3)
| | | Pack years current, 15+ vs. never | 1.4 (1.1; 1.9)
| | | Pack years Former, <15 vs. never | 1 (0.8; 1.4)
| | | Pack years former, 15+ vs. never | 1.7 (1.1; 2.6)
| | | Smoking Current vs. never | 1.1 (0.9; 1.5)
| | | Smoking Former vs. never | 1.1 (0.8; 1.4)
| | Total UI: larger amounts at least once a week, 56 g/24 hours | Cigarettes/day current, 20+ vs. never | 2.1 (1.5; 2.8)
| | | Cigarettes/day current, 1–19 vs. never | 1.3 (1.1; 1.5)
| | | Cigarettes/day former, >20 vs. never | 2.5 (1.8; 3.5)
| | | Cigarettes/day Former, 1–19 vs. never | 1.2 (1.1; 1.5)
| | | Pack years current, <15 vs. never | 1.1 (0.9; 1.4)
| | | Pack years current, 15+ vs. never | 1.7 (1.4; 2)
| | | Pack years Former, <15 vs. never | 1.2 (1; 1.4)
| | | Pack years former, 15+ vs. never | 2 (1.6; 2.6)
| | | Smoking Current vs. never | 1.4 (1.2; 1.6)
| | | Smoking Former vs. never | 1.4 (1.2; 1.6)
| | Urge UI: larger amounts at least once a week, 56 g/24 hours | Cigarettes/day current, 1–19 vs. never | 1.3 (0.1; 3.6)
| | | Cigarettes/day current, 20+ vs. never | 1.3 (0.8; 2.1)
| | | Cigarettes/day former, >20 vs. never | 2.1 (0.7; 6)
| | | Cigarettes/day Former, 1–19 vs. never | 1 (0.6; 1.7)
| | | Pack years current, 15+ vs. never | 1.1 (0.6; 2.1)
| | | Pack years current, <15 vs. never | 1.5 (0.8; 2.7)
| | | Pack years Former, <15 vs. never | 0.8 (0.4; 1.5)
| | | Pack years former, 15+ vs. never | 2.8 (1.5; 5.2)
| | | Smoking Current vs. never | 1.2 (0.7; 1.9)
| | | Smoking Former vs. never | 1.1 (0.7; 1.8)
Miller, 2003 ^134^ | 21–79 | Even a small amount of urine in the previous month | Current smoker <20 per day vs. never | 1.26 (0.51; 3.14)
N = 1,500 | | | Current smoker ≥20 per day vs. never | 3.34 (1.6; 6.98)
Sampselle, 2002 ^151^ | 42–52 | Frequency score is multiplied by volume score | Current smoking vs. never | 1.38 (1.04; 1.82)
N = 3,302
Miller, 2003 ^134^ | 21–79 | Even a small amount of urine in the previous month | Ex-smoker vs. never | 1.37 (0.64; 2.9)
N = 1,500

Table F17 Association between cognitive status, depression, dependency, and UI in women

Author, Sample | Age | Definition UI | Risk Factors | Odds Ratio (95%CI)
Incident UI, Cognitive status
Ostbye, 2004 ^28^ | >65 | UI in the last 12 months | Cognitive status 50 3MS < 78 | 1.34 (0.78; 2.29)
N = 5,322 | | | Cognitive status 3MS < 50 | 2.77 (0.37; 20.62)
Huang, 2007 ^46^ | >65 | UI in the last 12 months | Decline in Mini-Mental State Examination (more than 1 SD decline) | 1.01 (0.86; 1.18)
N = 6,361 | | | Decline in Trails B (more than 1 SD decline) | 0.93 (0.79; 1.11)
| | | Decline in Digit Symbol Substitution test (more than 1 SD decline) | 0.88 (0.73; 1.07)
| | | Decline in walking speed | 1.31 (1.09; 1.56)
| | | Decline in chair stand speed | 1.4 (1.19; 1.64)
| | Urine leakage occurring at least 1/week that interfered with activities | Decline in Mini-Mental State Examination (more than 1 SD decline) | 1.55 (1.1; 2.17)
| | | Decline in Trails B (more than 1 SD decline) | 1.23 (0.84; 1.8)
| | | Decline in Digit Symbol Substitution test (more than 1 SD decline) | 1.53 (1; 2.31)
| | | Decline in walking speed | 1.44 (0.98; 2.12)
| | | Decline in chair stand speed | 1.21 (0.86; 1.69)
Incident UI, Depression
Jackson, 2004 ^22^ | 70–79 | UI at least weekly | Depressive symptoms CES-D ≥ 16 | 2.7 (1.4; 5.3)
N = 1,584
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | Depressive symptoms | 1.25 (0.96; 1.61)
N = 3,302
Prevalent UI, Cognitive
Ostbye, 2004 ^28^ | >65 | UI in the last 12 months | Cognitive status 50 3MS < 78 | 0.89 (0.58; 1.35)
N = 5,322 | | | Cognitive status 3MS < 50 | 1.64 (0.49; 5.46)
Landi, 2003 Landi, 2003 #937} | 79.5+-9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | Delirium | 1.66 (1.31; 2.11)
N = 3,194 | | | CPS score24 vs. 0–1 | 2.01 (1.64; 2.45)
| | | CPS score>5 vs. 0–1 | 6.11 (4.67; 7.99)
Prevalent UI, Dependency
McGrother, 2006 ^6^ | >40 | Stress UI, monthly or more | ADL 4 vs. 1 | 1 (0.5; 1.8)
N = 12,570
Nuotio, 2003 ^136^ | >70 | Stress UI, ever | ADL disability (1+) | 0.8 (0.3; 2)
N = 227
McGrother, 2006 ^6^ | >40 | Stress UI, monthly or more | ADL 2 vs. 1 | 0.8 (0.4; 1.3)
N = 12,570 | | Stress UI, monthly or more | ADL 3 vs. 1 | 1.1 (0.7; 1.7)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | Physical limitations moderate | 2.31 (1.52; 3.52)
N = 3,804 | | | Physical limitations severe | 2.66 (1.48; 4.77)
Fultz, 1999 ^357^ | >70 | Mild=0–6 days/month | Difficulties with ADLs | 1.87 (1.43; 2.45)
N = 3,991 | | Moderate=7–20days/month | Difficulties with ADLs | 1.87 (1.11; 3.14)
| | Severe ≥21 days/month | Difficulties with ADLs | 3.66 (2.83; 4.73)

Table F18 Risk factors for urinary incontinence in child-bearing women (pregnancy, post-partum, and up to 1 year post-delivery)

Author, Sample | Age | Definition of UI | Risk Factors | Odds Ratio (95%CI)
Maggi, 2001 ^158^ | >65 | UI at least once per week | ADL disability | 1.75 (1.22; 2.52)
N = 1,531 | | | Mobility disability | 1.81 (1.32; 2.49)
Nygaard, 2003 ^79^ | 50–69 | UI in the last 12 months | ADL | 1.44 (1.1; 1.88)
N = 5,701 | | | Functional status | 1.55 (1.35; 1.78)
| | | Functional status | 1.9 (1.49; 2.41)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Physical functioning score 51–75 vs. 76–100 | 1.3 (1; 1.8)
N = 1,017 | | | Physical functioning score 0–50 vs. 76–100 | 1.8 (1.2; 2.6)
| | Severe: Sandvik score of 6–8 over the past year | Physical functioning score 51–75 vs. 76–100 | 1.6 (1; 2.4)
| | | Physical functioning score 0–50 vs. 76–100 | 2.3 (1.5; 3.8)
Landi, 2003 Landi, 2003 #937} | 79.5±9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | 24 vs. 0–1 | 1.81 (1.3; 2.52)
N = 3,194 | | | >5 vs. 0–1 | 5.99 (4.68; 7.66)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | Physical limitations Moderate vs. none | 4.15 (2.85; 6.04)
N = 3,804 | | | physical limitations Severe vs. none | 5.21 (1.16; 8.61)
Prevalent UI, Depression
Waetjen, 2007 ^49^ | 42–52 | Mixed UI, at least monthly | Depressive symptoms | 1.45 (1.04; 2.03)
N = 3,302
Nuotio, 2003 ^136^ | >70 | Stress UI, ever | Depressed mood (2+ in GDS-5 vs. <2) | 2.1 (0.9; 5.2)
N = 227
Jackson, 2004 ^21^ | 70–79 | Stress UI, within the past week | Depressive symptoms (CES-D >16) | 2 (0.92; 4.34)
N = 1,584
Nygaard, 2003 ^79^ | 50–69 | Mild-moderate incontinence - incontinence on 15 or fewer days in the last month | Depression | 1.41 (1.06; 1.87)
N = 5,701 | | Severe incontinence-incontinence on more than 15 days in the last month | Depression | 1.82 (1.26; 2.63)
Melville, 2005 ^112^ | 30–90 | UI at least monthly. | Current major depression | 2.5 (1.7; 3.7)
N = 3,596 | | UI at least monthly | Current major depression | 1.8 (1.1; 2.9)
Moghaddas, 2005 ^359^ | 50–64 | Any leakage | Self-reported depression (yes) | 1.37 (1.21; 1.55)
N = 6,642
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | Depressive symptoms | 1.28 (1.02; 1.61)
N = 3,302 | | UI >weekly/daily | Depressive symptoms | 1.33 (0.99; 1.81)
Buchsbaum, 2002 ^144^ | 39–91 | “Current” UI | depression | 2.96 (1.21; 7.55)
N = 149
Landi, 2003 Landi, 2003 #937} | 79.5+-9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | Yes | 1.05 (0.88; 1.25)
N = 3,194
Jackson, 2004 ^21^ | 70–79 | Urge UI, within the past week | Depressive symptoms (CES-D >16) | 1.49 (0.98; 2.27)
N = 1,584

Table F18a Risk factors for urinary incontinence in child-bearing women (pregnancy, post-partum, and up to 1 year post-delivery)

Author, Sample | Age | Risk Factors | Odds Ratio (95%Cl)
Burgio, 1996 ^362^ | 523 postpartum women 14–42 years | White women: previous UI included in model:
| | Previous UI: | 15.8 | 6.7–37.3
| | Education: | 1.4 | 0.9–2.3
| | Nocturia: | 1.1 | 0.99–1.3
| | White women: previous incontinence not included in mode:
| | Education: | 1.7 | 1.1–2.6
| | Number of births: | 1.2 | 0.97–1.5
| | Nocturia: | 1.1 | 0.99–1.3
| | Black women: previous incontinence not included in model:
| | Attended class: | 4.0 | 1.4–12.1
| | BMI, smoking during pregnancy, number of pregnancies, coughing a lot, urinary frequency, family member has UI, income level were not associated with UI
Wilson, 1996 ^363^ | 1,505 women 3 months after delivery | All women:
| | Mode of delivery
| | Forceps | 1.1 | 0.8–1.6
| | Cesarean section | 0.4 | 0.3–0.6
| | Parity
| | 2 | 1.3 | 1–1.8
| | 3 | 1.4 | 1;2
| | 4 | 1.1 | 0.6–2
| | 5+ | 2.2 | 1–4.9
| | BMI | 1.07 | 1.04–1.1
| | Pelvic floor muscle exercises during pregnancy
| | None | 1
| | Few/month | 0.8 | 0.6–1.1
| | Weekly | 0.8 | 0.5–1.3
| | Few/week | 0.9 | 0.7–1.2
| | Daily All women: | 0.6 | 0.4–0.9
| | All women with no previous UI:
| | Mode of delivery
| | Forceps | 1.3 | 0.8–2.3
| | Cesarean section | 0.3 | 0.1–0.6
| | Parity
| | 2 | 1.5 | 1–2.4
| | 3 | 1 | 0.6–1.9
| | 4 | 1 | 0.4–2.9
| | 5+ | 0.9 | 0.1–8.2
| | BMI | 1.02 | 0.97–1.07
| | Pelvic floor muscle exercises during pregnancy
| | None | 1
| | Few/month | 0.8 | 0.4–1.6
| | Weekly | 0.9 | 0.4–2.3
| | Few/week | 1 | 0.6–1.6
| | Daily | 0.9 | 0.5–1.7
| | All primiparae:
| | Mode of delivery
| | Forceps | 1.1 | 0.7–1.7
| | Cesarean section | 0.4 | 0.2–0.7
| | BMI | 1.07 | 1.02–1.12
| | Pelvic floor muscle exercises during pregnancy
| | None | 1
| | Few/month | 0.7 | 0.4–1.3
| | Weekly | 0.8 | 0.4–1.7
| | Few/week | 0.8 | 0.5–1.4
| | Daily | 0.6 | 0.3–1
| | Primiparae with no previous UI:
| | Mode of delivery
| | Forceps | 1 | 0.5–1.9
| | Cesarean section | 0.2 | 0–0.6
| | BMI | 1.07 | 1–1.14
| | Pelvic floor muscle exercises during pregnancy
| | None | 1
| | Few/month | 1.4 | 0.5–3.5
| | Weekly | 1.2 | 0.4–3.9
| | Few/week | 1.1 | 0.5–2.3
| | Daily | 0.8 | 0.3–1.9
Højberg, 1999 ^39^ | 7,795 nulliparous and multiparous women | UI at least once/week
| | Age:
| | 15–24 years: 1 | 1.5 | 1.0–2.4
| | 25–29years: Reference
| | 30–34 years: | 1.3 | 0.9–1.8
| | > 35 years: | 1.2 | 0.8–1.9
| | Parity:
| | 1; First delivery, C-section: | 1.3 | 0.4–4.3
| | 1; First delivery, vaginally: | 5.7 | 3.9–8.3
| | 2; Only C-sections: — | | —
| | 3+; Only vaginal deliveries: | 4.8 | 3.0–7.9
| | 3+; only C-section: — | | —
| | 3; Only vaginal deliveries: | 7.7 | 3.9–15.3
| | Pre-pregnancy BMI
| | < 20: | 1 | 0.7–1.3
| | 20–30: reference | | —
| | 30–35: | 1.7 | 0.9–3.2
| | > 35: | 2.5 | 1.0–6.0
| | Smoker: | 1.4 | 1.0–1.8
| | Previous miscarriages before 12^th^ week: | 1.1 | 0.8–1.5
| | Previous miscarriage after 12^th^ week: | 1.6 | 0.9–2.9
| | Previous lower abdominal or urological surgery: | 1.2 | 0.8–1.8
| | Association with SUI or MUI at 16 weeks gestation:
| | Length of second stage (min)
| | > 90: | 0.7 | 0.2–2.3
| | Episiotomy: | 1.9 | 1.0–3.5
| | Spontaneous perineal laceration > 3 cm: | 1.3 | 0.5–3.2
| | Vacuum extraction: | 0.6 | 0.3–1.6
| | Vaginal laceration: | 1.2 | 0.6–2.2
| | Third degree anal tear: | 0.01 | 0–0
| | Infant weight (g)
| | ≥ 4000: | 1.9 | 1.0–3.6
| | Time since last delivery (years)
| | ≤ 1 year: | 1.8 | 1.0–3.6
| | Oxytocin stimulation: | 1 | 0.6–1.9
| | Pudental block: | 1.2 | 0.7–2.0
Farrell, 2001 ^364^ | 595 primiparae with vaginal and cesarean deliveries | UI at 6 months post-delivery:
| | Duration of passive second stage of labor | 1.0 | 1.0–1.01
| | Duration of epidural | 1.0 | 0.9–1.0
| | Forceps delivery | 1.3 | 0.6–2.5
| | Relative risk:
| | UI at 6 weeks:
| | Spontaneous vaginal delivery vs. cesarean delivery: | 2.8 | 1.5–5.3
| | Forceps vs. spontaneous vaginal | 1.5 | 1.1–2.2
| | Forceps vs. cesarean:
| | | 4.3 | 2.2–8.2
| | Labored cesarean vs. elective cesarean | 2.3 | 0.3–17.6
| | Cesarean in second stage vs. elective cesarean | 1.2 | 0.1–12.2
| | Cesarean in labor vs. spontaneous vaginal | 0.4 | 0.2–0.8
| | UI at 6 months:
| | Spontaneous vaginal delivery vs. cesarean delivery: | 2.1 | 1.1–3.7
| | Forceps vs. spontaneous vaginal | 1.5 | 1.0–2.3
| | Forceps vs. cesarean:
| | | 3.1 | 1.7–5.9
| | Labored cesarean vs. elective cesarean | 2.5 | 0.3–18.5
| | Cesarean in second stage vs. elective cesarean | 0.6 | 0.04–9.1
| | Cesarean in labor vs. spontaneous vaginal | 0.6 | 0.3–1.0
| | Vacuum extraction showed similar risk as forceps at 6 months postpartum
Pregazzi, 2002 ^150^ | 537 primiparae and multiparae women with vaginal deliveries | Labor onset conditions (spontaneous or induced with intravaginal dinoprostone)
| | Asymptomatic women | 1.736 | 1.060–2.843
| | Women with stress incontinence | 0.492 | 0.273–0.885
Thompson, 2002 ^154^ | 1,295 primiparae and multiparae with vaginal and cesarean deliveries | Urinary incontinence at 8 weeks unassisted vaginal deliveries, women with cesarean sections | 0.25 | 0.14–0.44
| | Urinary incontinence at 16 weeks unassisted vaginal deliveries, women with cesarean sections | 0.59 | 0.35–0.99
| | Urinary incontinence at 24 weeks unassisted vaginal deliveries, women with cesarean sections | 0.55 | 0.31–0.98
Burgio, 2003 ^122^ | 523 aged 14–42 primiparae and multiparae with vaginal and cesarean deliveries | Time (month) | 1.02 | 0.984; | 1.055
| | Age (year) | 1.007 | 0.957; | 1.061
| | Race (black) | 0.699 | 0.328; | 1.486
| | Education( > college) | 0.629 | 0.382; | 1.034
| | Frequency of urination | 1.123 | 1.057; | 1.194
| | Smoking | 2.934 | 1.366; | 3.852
| | Type of delivery (vaginal) | 2.36 | 1.361; | 4.088
| | Body mass index | 1.055 | 1.016; | 1.094
| | Incontinent during pregnancy | 2.002 | 1.204; | 3.327
| | Length of breastfeeding | 1.169 | 1.022; | 1.339
| | Forceps | 1.87 | 1.085; | 3.222
Hvidman, 2003 ^130^ | 376 20–59 years: primiparae and multiparae with vaginal and cesarean deliveries | Predictors of postpartum UI after last delivery:
| | UI before index pregnancy | 4.7 | 2.4–9.0
| | UI during index pregnancy | 7 | 3.7–13.3
| | Index delivery by cesarean section | 0.2 | 0.06–0.9
| | Years since last index delivery | 0.8 | 0.6–1.0
| | Postpartum UI ≥ 4 weeks:
| | UI during index pregnancy | 11.1 | 5.7–21.8
| | Perineal suturing at index delivery | 2.4 | 1.2–4.8
| | Vacuum extraction or forceps delivery | 0.2 | 0.03–0.8
| | Years since index delivery | 0.7 | 0.6–1.0
| | Postpartum UI ≥ 12 weeks
| | UI before index pregnancy | 4 | 1.6–9.9
| | Perineal suturing at index delivery | 2.9 | 1.6–9.9
| | Years since index delivery | 0.6 | 0.4–0.9
| | Depending on model: variables not associated were: age, childhood enuresis, BMI > 30, cystitis, abdominal and/or gynecologic surgery, number of deliveries (total and vaginal), information on index delivery (augmentation, mode of delivery, episiotomy, vacuum/forceps, bladder catheter, birth weigh, breast-feeding
Eliasson, 2005 ^365^ | 665 nulliparous women | Inability to interrupt urine flow | 2.1 | 1.5–3.1
| | Perceived discomfort in lower abdomen | 3.6 | 2.3–5.9
| | Varicose veins/hemorrhoids | 1.5 | 1.0–2.2
| | Pre-pregnancy high impact activity | 1.4 | 1.0–2.0
| | Variables that were not associated were: pre-pregnancy leakage, partus normal, regular physical activity, chronic disease, age > 25 years, straining during micturition, and university studies
Glazener, 2006 ^5^ | 3,405 nulliparous women with singleton births | Primiparae who are first incontinent after their index delivery compared with continent primiparae
| | Age of mother at index birth
| | <25 | 1
| | 25–29 | 1.52 | 1.18–1.94
| | 30–34 | 1.46 | 1.10–1.94
| | >35 | 2.21 | 1.47–3.33
| | Delivery type
| | SVD | 1 | 0.87–1.46
| | Forceps/breech | 1.12 | 0.81–1.63
| | Vacuum | 1.14 | 0.19–0.42
| | Caesarean section | 0.29 | 0.52–1.38
| | Gestational age (weeks)
| | <37 | 1
| | >37 | 0.85 | 0.91–1.75
| | Birth weight (quartiles) (kg)
| | <3 | 1
| | 3.00–3.35 | 1.26 | 1.00–2.02
| | 3.36–3.69 | 1.42 | 0.90–1.96
| | >3.70 | 1.33 | 0.67–1.30
| | Head circumference (quartiles)
| | <35 | 1
| | 335–344 | 0.93 | 0.54–1.09
| | 345–354 | 0.77 | 0.52–1.12
| | >355 | 0.76 | 0.75–1.38
| | BMI before pregnancy (quartiles)
| | <20.7 | 1
| | 20.7–22.3 | 1.02 | 0.70–1.30
| | 22.4–25 | 0.95 | 0.95–1.79
| | >25 | 1.3 | 0.71–1.35
| | primiparae who are first incontinent after their index delivery compared with continent primiparae
| | Age of mother at index birth
| | <25 | 1
| | 25–29 | 1.46 | 1.15–1.86
| | 30–34 | 1.43 | 1.08–1.88
| | >35 | 2.02 | 1.35–3.02
| | Delivery type
| | SVD | 1
| | Forceps/breech | 1.18 | 0.92 –1.51
| | Vacuum | 1.16 | 0.83–1.63
| | Caesarean section | 0.28 | 0.19–0.41
| | primiparae who are first incontinent during their index delivery compared with continent primiparae
| | Age of mother at index birth
| | <25 | 1
| | 25–29 | 0.9 | 0.68–1.18
| | 30–34 | 0.9 | 0.66–1.24
| | >35 | 1.47 | 0.92–2.35
| | Delivery type
| | SVD | 1
| | Forceps/breech | 0.81 | 0.58–1.11
| | Vacuum | 1.05 | 0.70–1.59
| | Caesarean section | 0.39 | 0.27–0.59
| | Gestational age (weeks)
| | <37 | 1
| | >37 | 0.73 | 0.40–1.34
| | Birth weight (quartiles) (kg)
| | <3 | 1
| | 3.00–3.35 | 1.42 | 0.96–2.10
| | 3.36–3.69 | 1.72 | 1.14–2.60
| | >3.70 | 1.82 | 1.16–2.86
| | Head circumference (quartiles)
| | <335 | 1
| | 335–344 | 0.88 | 0.60–1.30
| | 345–354 | 0.73 | 0.48–1.09
| | >355 | 0.8 | 0.52–1.25
| | BMI before pregnancy (quartiles)
| | <20.7 | 1
| | 20.7–22.3 | 1.49 | 1.03–2.15
| | 22.4–25 | 1.35 | 0.93–1.96
| | >25 | 1.6 | 1.09–2.35
| | Delivery type
| | SVD | 1
| | Forceps/breech | 0.8 | 0.59–1.10
| | Vacuum | 1.06 | 0.72–1.57
| | Caesarean section | 0.39 | 0.27–0.58
| | Birth weight (quartiles) (kg) | 1
| | <3 | 1.33 | 0.95–1.85
| | 3.00–3.35 | 1.45 | 1.05–2.02
| | 3.36–3.69 | 1.56 | 1.12–2.19
| | >3.70
| | BMI before pregnancy (quartiles) | 1
| | <20.7 | 1.48 | 1.04–2.12
| | 20.7–22.3 | 1.38 | 0.96–1.99
| | 22.4–25 | 1.68 | 1.16–2.43
| | >25 | 1.39 | 0.96–2.02
Burgio, 2007 ^366^ | 759; mean age of 28.1 | Antenatal UI | 3.5 | 2.4–5.2
| 335 sphincter tear | No college education | 2 | 1.4–2.8
| 319 vaginal delivery without tear | Higher pre delivery BMI | 1.2 | 1.1–1.4
| 105 Cesarean delivery | Cesarean delivery | 0.5 | 0.3–0.9
Casey, 2005 ^367^ | 3,387 nulliparous women with vaginal and Cesarean deliveries | Oxytocin augmentation | 1.2 | 0.9–1.7
| | Epidural analgesia | 0.9 | 0.6–1.3
| | Second stage > 2 hours | 1.1 | 0.6–2.0
| | Episiotomy | 1.4 | 0.98–1.9
| | 3^rd^ or 4^th^ degree laceration | 1.1 | 0.7–1.9
| | Forceps delivery | 1.5 | 0.8–2.6
| | Cesarean delivery | 0.5 | 0.3–0.8
| | Birth weight > 4000 grams | 1.0 | 0.5–1.9
Schytt, 2004 ^30^ | 2,390 primiparae and multiparae with vaginal and Cesarean deliveries | Stress incontinence Primiparas
| | Age (years)
| | <25 | 0.9 | 0.6–1.2
| | 25–35 | 1
| | >35 | 1.3 | 0.8–2.2
| | Education
| | Elementary school | 1
| | High school | 2.5 | 0.8–7.7
| | College or university | 2.9 | 0.9–8.7
| | Civil status
| | married/cohabitant | 1
| | single | 1.6 | 1.1–2.5
| | Native language
| | Swedish | 1
| | Other than Swedish | 1 | 0.6–1.7
| | Multiparas
| | Age (years)
| | <25 | 1.1 | 0.7–1.7
| | 25–35 | 1
| | >35 | 1.2 | 1.0–1.6
| | Education
| | Elementary school | 1
| | High school | 0.9 | 0.6–1.3
| | College or university | 1.1 | 0.8–1.7
| | Civil status
| | married/cohabitant | 1
| | single | 1 | 0.6–1.7
| | Native language
| | Swedish | 1
| | Other than Swedish | 1.4 | 1.1–1.8
| | Stress incontinence Primiparas
| | Pregravida BMI
| | Underweight (<18.5) | 0
| | Normal (18.5–24.9) | 1
| | Overweight (25–29.9) | 1.2 | 0.9–1.6
| | Obesity (>30) | 1.5 | 1.1–2.0
| | Current pregnancy
| | Constipation*
| | Third trimester | 1.3 | 1.0–1.7
| | 4–8weeks postpartum | 1.5 | 1.1–2.0
| | 1 year after birth | 1.2 | 0.9–1.8
| | Urinary incontinence (overall)
| | Third trimester | 2.1 | 1.6–2.7
| | 4–8weeks postpartum | 3.2 | 2.7–3.8
| | Mode of delivery
| | Vaginal | 1
| | Vacuum extraction or forceps | 1.1 | 0.8–1.6
| | Elective cesarean section | 0
| | Emergency cesarean section | 0.6 | 0.3–1.0
| | Presentation (vaginal delivery)
| | Vertex | 1
| | Occiput posterior | 1.6 | 1.0–2.8
| | Breech | 0
| | Other | 0
| | Infant birth weight (g)
| | <2500 | 0.9 | 0.4–2.1
| | 2500–3499 | 1
| | 3500–4499 | 1.1 | 0.8–1.4
| | >4500 | 1 | 0.4–2.3
| | Infant head circumference (cm)
| | <33 | 1
| | 34 | 1.2 | 0.8–1.9
| | 35 | 1.2 | 0.8–1.9
| | 36 | 1.5 | 1.0–2.3
| | >37 | 1.1 | 0.6–1.8
| | Spontaneous perineal rupture
| | No perineal rupture | 1
| | First- and second degree | 1.3 | 1.0–1.7
| | Third- and fourth degree | 1.2 | 0.7–2.2
| | Episiotomy* | 1.2 | 0.9–1.6
| | Smoking* | 0.7 | 0.5–0.9
| | Prior to pregnancy
| | Early pregnancy | 1 | 0.6–1.5
| | 2months after birth | 1 | 0.6–1.6
| | 1 year after birth | 0.8 | 0.6–1.2
| | Multiparas
| | Number of children
| | 1 child | 1
| | 2 children | 0.9 | 0.7–1.1
| | 3–8 children | 1 | 0.7–1.4
| | Previous mode of delivery*
| | Vaginal (at least once) | 1
| | Cesarean section (exclusive) | 0.9 | 0.6–1.2
| | Pregravida BMI
| | Underweight (<18.5) | 1.4 | 0.6–3.2
| | Normal (18.5–24.9) | 1
| | Overweight (25–29.9) | 1.1 | 0.8–1.4
| | Obesity >30) | 1.3 | 1.0–1.6
| | Current pregnancy Constipation*
| | Third trimester | 1.3 | 1.1–1.6
| | 4–8weeks postpartum | 1.3 | 1.0–1.6
| | 1 year after birth | 1.1 | 0.8–1.4
| | Urinary incontinence (overall)
| | Third trimester | 2.9 | 2.4–3.5
| | 4–8weeks postpartum | 3.1 | 2.4–3.9
| | Mode of delivery
| | Vaginal | 1
| | Vacuum extraction or forceps | 1.5 | 1.0–2.3
| | Elective cesarean Section | 0.5 | 0.3–0.9
| | Emergency cesarean section | 0.5 | 0.3–1.0
| | Presentation (vaginal delivery)
| | Vertex | 1
| | Occiput posterior | 1.1 | 0.7–1.9
| | Breech | 0
| | Other | 0
| | Infant birth weight (g)
| | <2500 | 1.8 | 1.0–3.2
| | 2500–3499 | 1
| | 3500–4499 | 1.5 | 1.2–1.9
| | >4500 | 1.3 | 0.8–2.0
| | Infant head circumference (cm)
| | <33 | 1
| | 34 | 1 | 0.7–1.6
| | 35 | 1.4 | 0.9–2.0
| | 36 | 1.3 | 0.9–1.9
| | >37 | 1.1 | 0.7–1.6
| | Spontaneous perineal rupture
| | No perineal rupture | 1
| | First- and second degree | 1.4 | 1.2–1.7
| | Third- and fourth degree | 1.5 | 0.7–3.2
| | Episiotomy* | 0.9 | 0.6–1.5
| | Smoking*
| | Prior to pregnancy | 1.2 | 1.0–1.5
| | Early pregnancy | 1.3 | 0.9–1.7
| | 2months after birth | 1.2 | 0.9–1.6
| | 1 year after birth | 1.2 | 1.0–1.5
| | All women
| | Age (years) >35 | 1.5 | 1.0–2.1
| | Parity: Multiparas | 1.4 | 1.1–1.8
| | Pregravida BMI: Obesity | 1.5 | 1.0–2.2
| | Constipation
| | 4–8weeks after childbirth | 1.4 | 1.1–1.9
| | Urinary incontinence | 5.7 | 4.3–7.6
| | (overall leakage of urine)
| | 4–8weeks
| | After childbirth
| | Mode of delivery
| | Vaginal | 1
| | Vacuum extraction or forceps | 1.1 | 0.7–1.8
| | Cesarean section | 0.5 | 0.3–0.9
| | Spontaneous perineal rupture
| | No perineal rupture | 1
| | First-and second degree | 1.2 | 1.0–1.6
| | Third-and fourth degree | 1 | 0.4–2.5
Chaliha, 1999 ^326^ | 549 primiparae with vaginal and cesarean deliveries | Urge
| | Augmentation | 24.3 | 0.8, 728.7
| | Epidural | 0.1 | 0.0, 2.3
| | Cesarean compared with spontaneous and instrumental vaginal deliveries | 0.5 | 0.2, 1.1
| | Perineal trauma | 0.5 | 1.0, 2.8
| | First stage | 1 | 1.0, 1.0
| | Second stage (active) | 1 | 1.0, 1.0
| | Second stage (passive) | 1 | 1.0, 1.1
| | Fetal weight | 11.3 | 0.4, 352.8
| | Fetal head circumference | 2 | 0.7, 5.7
| | Stress
| | Augmentation | 0.9 | 0.5, 2.1
| | Epidural | 0.5 | 0.2, 1.3
| | Cesarean compared with spontaneous and instrumental vaginal deliveries | 1 | 0.8, 1.2
| | Perineal trauma | 1.1 | 0.7, 1.7
| | First stage | 1 | 1.0, 1.0
| | Second stage (active) | 1 | 1.0, 1.0
| | Second stage (passive) | 1 | 1.0, 1.0
| | Fetal weight | 2.5 | 1.1, 6.1
| | Fetal head circumference | 0.8 | 0.7, 1.1

Table F19 Association between hormonal status and prevalent UI in females

Author, Sample | Age | Definition of UI | Menstrual status | Odds ratio (95%CI)
Kuh, 1999 ^179^ | 48 | Stress UI ≥2/hour during the day and at ≥2/night | Naturally postmenopausal (by 48 y) | 0.54 (0.32; 0.91)
N = 1,333
Sampselle, 2002 ^151^ | 42–52 | Frequency score is multiplied by volume score | Perimenopausal vs. premenopausal | 1.27 (1.09; 1.49)
N = 3,302 | | Frequency score is multiplied by volume score | Perimenopausal status | 1.35 (1.1; 1.65)
Chen, 2003 ^123^ | >20 | Stress UI within the past 2 weeks | Menopause vs. premenopausal | 0.81 (0.4; 1.6)
N = 1,247
Moghaddas, 2005 ^359^ | 50–64 | UI: any leakage | Premenopausal | 1.44 (1.13; 1.82)
N = 6,642 | | | Premenopausal women with depression | 1.47 (1.1; 2.02)
| | | Premenopausal | 1.39 (0.97; 1.99)
Hvidman, 2003 ^356^ | 20–59 | UI in the past week | Bleeding | 0.8 (0.5; 1.4)
N = 3,900 | | | Bleeding use of sanitary towels vs. none | 0.8 (0.4; 1.4)
| | | Bleeding, amount Weak vs. none | 0.5 (0.2; 1.4)
| | | Bleeding, amount Medium vs. none | 0.9 (0.5; 1.4)
| | | Bleeding, amount Heavy vs. none | 1.1 (0.8; 1.5)
| | | Days before expected end of menstrual cycle-15 days | 0.6 (0.2; 2)
| | | Days before expected end of menstrual cycle-6–10 days | 1 (0.4; 2.4)
| | | Days since day one in present menstrual cycle11–15 days | 2.1 (1.1; 4)
| | | Days before expected end of menstrual cycle16–20 days | 1.1 (0.5; 2.4)
| | | Days since day one in present menstrual cycle Days 15 | 0.8 (0.4; 1.4)
| | | Days since day one in present menstrual cycle Days 6–10 | 1 (0.6; 1.9)
| | | Days since day one in present menstrual cycle Days 11–15 | 1.3 (0.7; 2.4)
| | | Days since day one in present menstrual cycle Days 16–20 | 1.2 (0.6; 2.2)
| | | Days since day one in present menstrual cycle Days 21–25 | 1.1 (0.5; 2.1)
| | | Days since day one in present menstrual cycle Days 26–30 | 0.5 (0.2; 1.6)
| | | Days since day one in present menstrual cycle Days 31–35 | 1.2 (0.3; 4.9)
| | | Days since day one in present menstrual cycle Unknown | 1.2 (0.7; 2.1)
| | | Decreased duration of bleeding | 2.2 (1.3; 3.6)
| | | Increased duration of bleeding | 1.4 (0.7; 2.9)
| | | Increased menstrual flow | 1.2 (0.7; 2.1)
| | | Recent change in menstrual cycle and bleeding | 1.5 (1; 2.3)
| | | Usual duration of menstrual cycle <21 days vs. 21–31 days | 1.2 (0.2; 9.4)
| | | Usual duration of menstrual cycle >32 days vs. 21–31 days | 1.2 (0.4; 3.4)
| | | Usual duration of menstrual cycle >35 days vs. 21–31 days | 1.1 (0.3; 4.8)
| | | Variation of menstrual cycle duration <5 days vs. 6–13 days | 1.1 (0.6; 1.9)
| | | Variation of menstrual cycle duration ≥5 days vs. 6–13 days | 1 (0.5; 2)
| | | Variation of menstrual cycle duration ≥14 days vs. 6–13 days | 0.8 (0.2; 3.4)
| | | Variation of menstrual cycle duration ≥30 days vs. 6–13 days | 1.3 (0.2; 10.1)
| | | Menstrual cycle and/or bleeding more irregular | 1.2 (0.6; 2.3)
| | | Menstrual cycle duration 21–32 days and variation range <5 days | 1.4 (0.9; 2.4)
| | | Menstrual cycle duration 21–32 days and variation range <5 days, no hormone use | 1.3 (0.8; 2)
| | | Menstrual cycle regularity, Regular | 1.2 (0.7; 1.9)
| | | Menstrual cycle regularity, Irregular | 0.9 (0.5; 1.7)

Bold - significant association at 95% level

Table F20 Association between prevalent UI and hysterectomy

Author, Sample | Age | Definition of UI | Odds Ratio (95%CI)
Stress
Chiarelli, 1999 ^173^ | 45–50 | UI in the past year | 0.78 (0.69; 0.88)
N = 41,724 | 70–75 | UI in the past year | 1.13 (0.97; 1.31)
Van der Vaart, 2002 ^155^ | 35–70 | Not bothersome UI | 1.18 (0.88; 1.59)
N = 1,626 | 35–70 | Bothersome UI | 1.18 (0.69; 1.86)
Parazzini, 2003 ^138^ | >40 | UI in the past month | 1.4 (1; 1.9)
N = 2,205
Jackson. 2004 ^21^ | 70–79 | UI in the past week | 1.47 (0.97; 2.23)
N = 1,584
Fritel, 2005 ^110^ | 49–61 | Daily | 1.1 (0.9; 1.5)
N = 2,625
Total UI
Parazzini, 2003 ^138^ | >40 | UI in the past month | 1.6 (1.1; 2.1)
N = 2,205
Brown, 1996 ^194^ | 69–101 | Daily | 1.4 (1.1; 1.6)
N = 7,949
Holtedahl, 1998 ^355^ | 50–74 | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | 1.07
N = 507 | | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | 1.15
Bortolotti, 2000 ^165^ | ≥40 | UI in the past year | 1.5 (0.9; 2.6)
N = 2,767
Schmidbauer, 2001 ^62^ | ≥20 | UI in the past month | 1.35 (1.1; 1.65)
N = 1,262
Melville, 2005 ^112^ | 30–90 | UI at least monthly | 1.3 (1.1; 1.6)
N = 3,596 | | UI at least monthly. Severe: Sandvik severity index score of 6–8 | 1.6 (1.2; 2)
Moghaddas, 2005 ^359^ | 50–64 | Any leakage | 1.21 (1; 1.45)
N = 6,642 | | Any leakage | 1.1 (0.79; 1.41)
Danforth, 2006 ^68^ | 25–54 | Occasional UI: 1–3 times a month. | 1.2 (1.1; 1.3)
N = 83,355 | | Frequent UI: At least weekly. | 1.4 (1.3; 1.5)
| | Severe: Wet underwear. | 1.6 (1.5; 1.7)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | 1.2 (0.9; 1.5)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | 1.5 (1; 2.1)
Urge UI
Kuh, 1999 ^179^ | 48 | At least two hourly during the day and at least twice a night | 1.3 (0.93; 2)
N = 1,333
Ueda, 2000 ^172^ | 40–75 | 1 = Never, 2 = Seldom, 3 = Sometimes, 4 = Very Often | 1.611 (1.051; 2.469)
N = 968
Van der Vaart, 2002 ^155^ | 35–70 | Not bothersome | 1.93 (1.4; 2.63)
N = 1,626 | | Bothersome | 2.63 (1.39; 4.41)
Parazzini, 2003 ^138^ | >40 | UI in the past month | 1.5 (1; 2.3)
N = 2,205

Bold- significant association at 95% confidence level

Table F21 Association between prevalent UI and gynecological factors

Author, Sample | Age | Definition of UI | Strata of Risk Factors | Odds Ratio (95%CI)
Mixed UI
Waetjen, 2007 ^49^ | 42–52 | UI at least monthly | Fibroids | 1.46 (0.99; 2.15)
N = 3,302
Parazzini, 2003 ^138^ | >40 | UI in the past month | Hysterectomy | 1.6 (1.1; 2.1)
N = 2,205
Stress UI
Chen, 2003 ^123^ | >20 | UI in the past 2 weeks | Previous gynecological surgery vs. none | 2 (1.1; 3.7)
N = 1,247
Huang, 2006 ^70^ | 40–69 | UI at least weekly in the pas 7 days | Hysterectomy in Asian women | 2.79 (1.03; 7.54)
N = 345 Asian women
Van der Vaart, 2002 ^155^ | 35–70 | UI not bothersome | Hysterectomy | 1.18 (0.88; 1.59)
N = 1,626 | | UI bothersome | Hysterectomy | 1.18 (0.69; 1.86)
Parazzini, 2003 ^138^ | >40 | UI in the past month | Hysterectomy | 1.4 (1; 1.9)
N = 2,205
Jackson, 2004 ^21^ | 70–79 | UI in the past week | Hysterectomy | 1.47 (0.97; 2.23)
N = 1,584
Fritel, 2005 ^110^ | 49–61 | Often or all of the time | Hysterectomy | 1.1 (0.9; 1.5)
N = 2,625
Total
Brown, 1996 ^194^ | 69–101 | Daily | Grip strength (kg per SD) | 1 (0.9; 1.1)
N = 7,949 | | | Quadriceps strength (kg per SD) | 0.9 (0.8; 1.1)
Thom, 1997 ^193^ | ≥60 | Within the past year | Hysterectomy <45 y vs. >45 | 1.41 (0.89; 2.23)
N = 933 | | Within the past year | Hysterectomy <45 y vs. >45 | 1.54 (0.87; 2.74)
Holtedahl, 1998 ^355^ | 50–74 | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Result of gynecological examination (abnormal vs. normal) | 1.77
N = 507 | | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Result of gynecological examination (abnormal vs. normal) | 2.86
| | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Pelvic muscle contraction (poor vs. good) | 4.5
| | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Pelvic muscle contraction (poor vs. good) | 3.48
| | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Previous operation for uterovaginal prolapse (yes vs. no) | 4.28
| | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Other previous operation on uterus (excluding hysterectomies) /adnexae/ovaries (yes vs. no) | 1.86
| | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Previous operation for uterovaginal prolapse (yes vs. no) | 5.3
| | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Other previous operation on uterus (excluding hysterectomies) /adnexae/ovaries (yes vs. no) | 2.24
Bortolotti, 2000 ^165^ | ≥40 | Within the past year | Perineal trauma | 0.8 (0.4; 1.8)
N = 2,767
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Wertheim | 1.26 (0.85; 1.85)
N = 1,262
Van Oyen, 2002 ^157^ | ≥15 | At least once a week, at least once a month, less than once a month | Uterine prolapse | 4.11 (2.15; 7.86)
N = 3,804
Sampselle, 2002 ^151^ | 42–52 | Frequency score is multiplied by volume score | History of leiomyomata for all ethnic groups but black | 1.13 (0.88; 1.45)
N = 3,302
Hvidman, 2003 ^356^ | 20–59 | Within the past seven days | Ever gynecologic operation | 1.6 (1; 2.5)
N = 3,900
Uustal-Fornel, 2004 ^208^ | 40 yr and 60 yr | Leakage weekly or more often | Feeling of pelvic heaviness vs. none | 3.8 (2.1; 7)
N = 1,336
Moghaddas, 2005 ^359^ | 50–64 | Any leakage | Hysterectomy (yes)Women with depression | 1.33 (1.04; 1.7)
N = 6,642
Brown, 2006 ^95^ | >20 | Weekly urinary incontinence | Weekly urinary incontinence | 2.29 (1.01; 5.2)
N = 1,461
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Any leakage in the past year | 1.5 (1; 2.1)
N = 1,017 | | | Any vaginal symptom (dryness, discharge, itching, dyspareunia) 1.6 | 1.6 (1.2; 2.2)
| | | Vaginal colonization w/E coli 1–3 growth | 0.9 (0.7; 1.2)
| | | Vaginal colonization w/E coli 4+ growth | 1.3 (0.8; 2)
| | Severe: Sandvik score of 6–8 over the past year | Atrophic vaginitis | 1.4 (0.9; 2.2)
| | | Any vaginal symptom (dryness, discharge, itching, dyspareunia) 1.6 | 1.6 (1; 2.7)
| | | Vaginal colonization w/E coli 1–3 growth | 1 (0.6; 1.7)
| | | Vaginal colonization w/E coli 4+ growth | 1.7 (1; 2.8)
Waetjen, 2007 ^49^ | 42–52 | frequency: at least monthly | Fibroids | 1.31 (1; 1.72)
N = 3,302
Brown, 1996 ^194^ | 69–101 | Daily | Hysterectomy vs. none | 1.4 (1.1; 1.6)
N = 7,949
Holtedahl, 1998 ^355^ | 50–74 | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Hysterectomy (yes vs. no) | 1.07
N = 507 | | 1–2 = Slight, 3–4 = Moderate, 6–8 = Severe | Hysterectomy (yes vs. no) | 1.15
Bortolotti, 2000 ^165^ | ≥40 | Within the past year | Hysterectomy | 1.5 (0.9; 2.6)
N = 2,767
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | hysterectomy | 1.35 (1.1; 1.65)
N = 1,262
Melville, 2005 ^112^ | 30–90 | Frequency: at least monthly. Severe: Sandvik severity index score of 6–8 | Hysterectomy | 1.3 (1.1; 1.6)
N = 3,596 | | Frequency: at least monthly. Severe: Sandvik severity index score of 6–8 | Hysterectomy | 1.6 (1.2; 2)
Moghaddas, 2005 ^359^ | 50–64 | Any leakage | Hysterectomy (yes) | 1.21 (1; 1.45)
N = 6,642 | | Any leakage | Hysterectomy (yes) | 1.1 (0.79; 1.41)
Danforth, 2006 ^68^ | 25–54 | Occasional: 1–3 times a month. | Hysterectomy | 1.2 (1.1; 1.3)
N = 83,355 | | Frequent: At least weekly. | Hysterectomy | 1.4 (1.3; 1.5)
| | Severe: Wet underwear. | Hysterectomy | 1.6 (1.5; 1.7)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Hysterectomy | 1.2 (0.9; 1.5)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | Hysterectomy | 1.5 (1; 2.1)
Chiarelli, 1999 ^173^ | 45–50 | Rarely, sometimes, often experience leaking urine in the last year | Hysterectomy+prolapse vs. none or unknown | 1.85 (1.53; 2.23)
N = 41,724 | | | Hysterectomy+oophorectomy vs. none or unknown | 1.05 (0.87; 1.27)
| | | Hysterectomy+prolapse+oophorecto my vs. none or unknown | 1.88 (1.34; 2.63)
| | | Prolapse vs. none or unknown | 2.41 (1.92; 3.04)
| | | Oophorectomy+prolapse vs. none or unknown | 0.75 (0.15; 3.82)
| | | Oophorectomy | 0.71 (0.39; 1.27)
| 70–75 | Rarely, sometimes, often experience leaking urine in the last year | Hysterectomy and oophorectomy vs. none or unknown | 1.18 (1.08; 1.38)
| | | Hysterectomy+prolapse repair vs. none or unknown | 2.03 (1.67; 2.47)
| | | Hysterectomy+prolapse repair+oophorectomy vs. none or unknown | 1.77 (1.44; 2.17)
| | | Prolapse repair vs. none or unknown | 1.73 (1.46; 2.06)
| | | Oophorectomy+prolapse repair vs. none or unknown | 1.97 (0.82; 4.67)
| | | Oophorectomy vs. none or unknown | 1.37 (0.81; 2.31)
Miller, 2003 ^134^ | 21–79 | Even a small amount of urine in the previous month | No Hysterectomy vs. yes | 0.67 (0.45; 0.99)
N = 1,500
Chiarelli, 1999 ^173^ | 45–50 | Rarely, sometimes, often experience leaking urine in the last year | Hysterectomy vs. none or unknown | 0.78 (0.69; 0.88)
N = 41,724 | | | Hysterectomy vs. none or unknown | 1.13 (0.97; 1.31)
Urge
Waetjen, 2007 ^49^ | 42–52 | Frequency: at least monthly | Fibroids | 1.53 (1.08; 2.27)
N = 3,302
Kuh, 1999 ^179^ | 48 | At least two hourly during the day and at least twice a night | Hysterectomy | 1.3 (0.93; 2)
N = 1,333
Ueda, 2000 ^172^ | 40–75 | 1 = Never, 2 = Seldom, 3 = Sometimes, 4 = Very Often | Hysterectomy | 1.611 (1.051; 2.469)
N = 968
Van der Vaart, 2002 ^155^ | 35–70 | Not bothersome | Hysterectomy | 1.93 (1.4; 2.63)
N = 1,626 | | Bothersome | Hysterectomy | 2.63 (1.39; 4.41)
Parazzini, 2003 ^138^ | >40 | Within the past month | Hysterectomy | 1.5 (1; 2.3)
N = 2,205

Table F22 Association between urinary symptoms and prevalent UI in women

Author, Year, Sample | Age | Definition UI | Urinary symptoms | Odds ratio (95%CI)
Chiarelli, 1999 ^173^ | 18–23 | UI in the last year | Urine that burns and stings: Rarely vs. never | 2.94 (2.59; 3.33)
N = 41,724 | | | Urine that burns and stings: Sometimes vs. never | 4.19 (3.56; 4.93)
| | | Urine that burns and stings: Often vs. never | 4.93 (3.64; 6.74)
| 45–50 | UI in the last year | Urine that burns and stings: Rarely vs. never | 2.17 (1.96; 2.42)
| | | Urine that burns and stings: Sometimes vs. never | 2.71 (2.35; 3.14)
| | | Urine that burns and stings: Often vs. never | 4.29 (2.85; 6.45)
| 70–75 | UI in the last year | Urine that burns and stings: Rarely vs. never | 2.45 (2.18; 2.76)
| | | Urine that burns and stings: Sometimes vs. never | 2.99 (2.62; 3.41)
| | | Urine that burns and stings: Often vs. never | 7.97 (5.71; 11.12)
Kuh, 1999 ^179^ | 48 | UI ≥2/hour during the day and ≥2/night | Enuresis | 2.9 (1.3; 6.9)
N = 1,333
Miller, 2003 ^134^ | 21–79 | UI even a small amount in previous month | Urine that burns and stings: Rarely vs. never | 0.68 (0.34; 1.37)
N = 1,500 | | | Urine that burns and stings: Sometimes vs. never | 0.78 (0.38; 1.62)
| | | Urine that burns and stings: Often vs. never | 4.06 (1.32; 12.48)
| | | Urine that burns and stings: Rarely vs. never | 1.3 (0.59; 2.89)
| | | Urine that burns and stings: Sometimes vs. never | 2.69 (1.5; 4.8)
| | | Urine that burns and stings: Often vs. never | 1.56 (0.79; 3.1)
| | | Urine that burns and stings: Unit increase in response category | 1.3 (1.04; 1.62)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | Urinary tract infections | 5.75 (3.35; 9.9)
N = 3,804 | | | Urinary tract infections | 4.39 (2.55; 7.51)
Kok, 1992 ^202^ | ≥60 | UI at least twice a week | Frequency | 3.52 (1.88; 6.59)
N = 719 | | | Nocturia | 4.03 (1.48; 10.98)
Bortolotti, 2000 ^165^ | ≥40 | UI in the past year | Enuresis | 1.3 (0.7; 2.4)
N = 2,767
Schmidbauer, 2001 ^62^ | ≥20 | UI in the past 4 weeks | Lower urinary tract symptoms | 1.15 (0.82; 1.62)
N = 1,262
Hvidman, 2003 ^356^ | 20–59 | UI in the past week | Enuresis | 2.8 (1.6; 5)
N = 3,900
Kocak, 2005 ^368^ | ≥18 | UI once a week or less- | UI once a week or less- | 3 (1.6; 8)
N = 1,012
Kuh, 1999 ^179^ | 48 | Urge UI: ≥2/hour during the day and ≥2/night | Enuresis | 2.7 (1.3; 5.6)
N = 1.333

Bold- significant association at 95% confidence level

Table F23 Association between urinary tract infection and prevalent UI in women

Author, Sample | Age | Definition of UI | Urinary tract infection | Odds ratio (95%CI)
Mixed UI
Brown, 1999 ^353^ | Mean: 67 (SD: 7) | UI in the past week | UTI in past year: 1 vs. 0 | 1.04 (0.73; 1.47)
N = 2,763 | | | UTI in past year: 2+ vs. 0 | 2.44 (1.51; 3.92)
Parazzini, 2003 ^138^ | >40 | UI in the past month | Recurrent UTIs | 1.9 (1.5; 2.4)
N = 2,205
Kuh, 1999 ^179^ | 48 | ≥2/hourl during the day and ≥2/night | Urinary or kidney infections (15–43 yr) | 1.6 (0.94; 2.6)
N = 1,333
Stress UI
Brown, 1999 ^353^ | Mean: 67 (SD: 7) | UI in the past week | UTI in past year: 1 vs. 0 | 1.04 (0.66; 1.85)
N = 2,763 | | | UTI in past year: 2+ vs. 0 | 1.51 (0.77; 2.97)
Kuh, 1999Kuh, 1999 ^179^ | 48 | UI at least two hourly during the day and at least twice a night | urinary or kidney infections (15–43 yr) | 1.1 (0.78; 1.5)
N = 1,333
Nuotio, 2003 ^136^ | >70 | Ever UI | UTI (1+/year vs. <1/year) | 0.9 (0.4; 2)
N = 227
Parazzini, 2003 ^138^ | >40 | UI in the past month | Recurrent UTIs | 1.3 (1; 1.8)
N = 2,205
Huang, 2006 ^70^ | 40–69 | UI at least weekly | Frequent UTIs in White women | 1.8 (1.05; -3.1)
N = 345 Asian women
Total UI
Bortolotti, 2000 ^165^ | ≥40 | UI in the past year | Recurrent UTI | 2.2 (1.4; 3.4)
N = 2,767
Buchsbaum, 2002 ^144^ | 39–91 | “Current” UI | UTI | 3.37 (1.23; 11.06)
N = 149
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | UTIs | 6.83 (4.43; 10.6)
N = 3,804
Hvidman, 2003 ^356^ | 20–59 | UI in the past week | Cystitis 1997 | 1.5 (0.8; 2.7)
N = 3,900
Landi, 2003 ^131^ | 79.5+-9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | UTI | 3.66 (2.51; 5.33)
N = 3,194
Ozerdogan, 2004 ^29^ | >20 | Ever UI | Recurrent UTIs | 4.7 (4.7; 8.9)
N = 625
Oskay, 2005 ^111^ | >50 | <1/month (rare) - >1/day (serious). Severity: drops lost, underwear wet, dresses wet, leaks through legs | UTI after menopause | 1.84 (1.18; 2.89)
N = 500
Kocak, 2005 ^368^ | ≥18 | Frequency: ≤1/week - always. Severity: small, moderate, large | Recurrent UTI | 2.3 (1.3; 3.9)
N = 1,012
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Asymptomatic bacteriuria | 1.3 (0.6; 2.6)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | Asymptomatic bacteriuria | 0.7 (0.3; 1.6)
| | Any leakage in the past year | Lifetime UTI's 1–5 | 1.2 (1; 1.7)
| | | Lifetime UTI's 6+ | 1.9 (1.4; 2.7)
| | | UTI in past year | 1.2 (0.8; 1.8)
| | Severe: Sandvik score of 6–8 over the past year | Lifetime UTI's 1–5 | 1.6 (1; 2.5)
| | | Lifetime UTI's 6+ | 2 (1; 2.5)
| | | UTI in past year | 1.4 (0.7; 2.6)
Brown, 1999 ^353^ | Mean: 67 (SD: 7) | UI in the past week | UTI in past year: 1 vs. 0 | 1.04 (0.68; 1.6)
N = 2,763 | | | UTI in past year: 2+ vs. 0 | 1.98 (1.1; 3.57)
Kuh, 1999 ^179^ | 48 | UI at least 2/x hour during the day and ≥2/night | Urinary or kidney infections (15–43 yr) | 1.2 (0.82; 1.7)
N = 1,333
Ueda, 2000 ^172^ | 40–75 | 1 = Never, 2 = Seldom, 3 = Sometimes, 4 = Very Often | Cystitis | 1.961 (1.459; 2.635)
N = 968
Parazzini, 2003 ^138^ | >40 | UI in the past month | Recurrent UTIs | 2.3 (1.6; 3.1)
N = 2,205
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | UTI | 5.75 (3.35; 9.9)
N = 3,804 | | UI at least once a month | UTI | 4.39 (2.55; 7.51)

Bold- significant association at 95% confidence level

Table F24 Association between glucose metabolism and UI

Author, Sample | Age | Definition | Risk Factor | Odds ratio (95%CI)
Incidence
Ostbye, 2004 ^28^ | >65 | In the last 12 months, have you lost any amount of urine beyond your control | Diabetes | 1.08 (0.8; 1.46)
N = 5,322
Lifford, 2005 ^109^ | 50–75 | Frequency: weekly amount: severe - wet underwear. Very severe - wet out clothing/floor | Diabetes >10 years (Any UI) | 1.47 (1.15; 1.89)
N = 81,845 | | Frequency: weekly amount: severe - wet underwear. Very severe - wet out clothing/floor | Diabetes >10 years (Severe UI) | 1.75 (1.32; 2.33)
| | Frequency: weekly amount: severe - wet underwear. Very severe - wet out clothing/floor | Diabetes >10 years (Very severe UI) | 2.62 (1.39; 4.96)
Waetjen, 2007 ^49^ | 42–52 | Frequency: at least monthly | Diabetes | 3.02 (1.12; 8.1)
N = 3,302
Prevalence
Nuotio, 2003 ^136^ | >70 | Stress UI, ever | Fasting glucose serum level, mg/dl Fecal incontinence vs. continence | 1 (0.8; 2.7)
N = 227
Sampselle, 2002 ^151^ | 42–52 | Stress UI, Frequency score is multiplied by volume score | Diabetes | 1.55 (1.07; 2.25)
N = 3,302
Fritel, 2005 ^110^ | 49–61 | Stress UI, often or all of the time | Diabetes | 1.8 (1; 3.2)
N = 2,625
Waetjen, 2007 ^49^ | 42–52 | Frequency: >weekly/daily | Diabetes | 3.1 (1.43; 6.74)
N = 3,302
Lifford, 2005 ^109^ | 50–75 | Severe - wet underwear. Very severe - wet out clothing/floor | Diabetes (Severe UI) | 1.4 (1.3; 1.6)
N = 81,845 | | Very severe - wet out clothing/floor | Diabetes (Very severe UI) | 1.8 (1.5; 2.1)
Jackson, 2005 ^101^ | 55–75 | Sandvik Index | Diabetes duration < 10 years | 1.4 (0.8; 2.6)
N = 1,017 | | Sandvik Index | Diabetes duration >10 years | 1.6 (0.7; 3.4)
| | Sandvik Index, mild UI | Diabetes treatment, diet | 1.3 (0.5; 2.8)
| | Sandvik Index | Diabetes treatment, insulin | 1.7 (0.6; 4.1)
| | Sandvik Index | Diabetes treatment, med | 1.5 (0.8; 2.9)
| | Sandvik Index | Diabetic peripheral neuropathy | 1.7 (0.9; 3.2)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Diabetic peripheral neuropathy treatment vs. no diabetes | 1.9 (1.1; 3.3)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | Diabetic peripheral neuropathy treatment vs. no diabetes | 1.2 (0.6; 1.8)
Jackson, 2005 ^101^ | 55–75 | Sandvik Index | Diabetic retinopathy | 1.9 (0.7; 4.8)
N = 1,017
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Diabetic retinopathy treatment vs. no diabetes | 1.4 (0.6; 3.6)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | Diabetic retinopathy treatment vs. no diabetes | 1.4 (0.4; 5.3)
| | Any leakage in the past year | Diet-treated diabetes treatment vs. no diabetes | 1.4 (0.9; 2.4)
| | Severe: Sandvik score of 6–8 over the past year | Diet-treated diabetes treatment vs. no diabetes | 1.5 (0.8; 3.1)
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | Fasting glucose serum level, mg/dl>123 vs. <110 | 1.22 (0.73; 2.03)
N = 1,262 | | | Fasting glucose serum level, mg/dl110– 123 vs. <110 | 1.44 (1.04; 2)
Jackson, 2005 ^101^ | 55–75 | Sandvik Index | HbA1c<7.5% | 1.4 (0.7; 2.6)
N = 1,017 | | Sandvik Index | HbA1c> 8.5% | 1.2 (0.3; 3.6)
| | Sandvik Index | HbA1c7.68.5% | 1.2 (0.4; 3)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Insulin treated diabetes vs. no diabetes | 1.4 (0.8; 2.6)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | Insulin treated diabetes vs. no diabetes | 0.5 (0.8; 2.7)
Brown, 2006 ^95^ | >20 | Weekly urinary incontinence | Microalbuminuria vs. no in diabetics | 0.98 (0.36; 2.71)
N = 1,461 | | | Microalbuminuria vs. no in impaired glucose tolerance | 7.45 (1.59; 34.98)
| | | Neuropathic pain (yes/no)in diabetics | 2.37 (1.27; 4.42)
Jackson, 2005 ^101^ | 55–75 | Sandvik Index | No Diabetic peripheral neuropathy | 1.4 (0.7; 2.7)
N = 1,017 | | | No Diabetic retinopathy | 1.1 (0.6; 2)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Pill-treated diabetes vs. no diabetes | 0.8 (0.5; 1.3)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | Pill-treated diabetes vs. no diabetes | 1.6 (0.9; 2.7)
Danforth, 2006 ^68^ | 25–54 | Frequent: At least weekly. | Type 2 Diabetes | 1.2 (1.1; 1.3)
N = 83,355 | | Severe: Wet underwear. | Type 2 Diabetes | 1.3 (1.2; 1.4)

Bold- significant association at 95% confidence level

Table F25 Association between neurological diseases and UI in women

Author, Sample | Age | Definition of UI | Risk Factors | Odds Ratio (95% CI)
Incident UI, Total UI
Ostbye, 2004 ^28^ | >65 | UI in the last 12 months | Stroke | 1.58 (1.13; 2.22)
N = 5,322
Prevalent UI, Total UI
Parazzini, 2003 ^138^ | >40 | UI in the past month | Neurological diseases | 3.7 (1.8; 7.3)
N = 2,205
Brown, 1996 ^194^ | 69–101 | UI daily | Gait speed (m/sec per SD) | 0.8 (0.6; 1)
N = 7,949 | | UI daily | Parkinson disease vs. none | 0.3 (0.1; 1.6)
Fultz, 1999 ^357^ | >70 | UI at least monthly | Poor sensory status | 1.94 (1.6; 2.35)
N = 3,991 | | Moderate =7–20days/month | Poor sensory status | 1.22 (0.82; 1.82)
| | Severe ≥21 days/month | Poor sensory status | 1.53 (1.2; 1.94)
Bortolotti, 2000 ^165^ | ≥40 | UI in the last 12 months | Neurological disease | 1.8 (0.7; 4.3)
N = 2,767
Maclennan, 2000 ^84^ | 15–97 | UI in the last 12 months | Osteoporosis | 1.8 (1; 3.2)
N = 3,010
Maggi, 2001 ^158^ | >65 | Rarely, 1 to 2 times per month, at least once per week, or every day | Parkinsonism | 2.27 (1.14; 4.54)
N =1,531
Ozerdogan, 2004 ^29^ | >20 | Ever | Neurological disorders | 3.8 (1.7; 8.6)
N = 625
Rohr, 2005 ^107^ | >45 | UI in the past month | Paraplegia | 1.56 (1.14; 2.64)
N = 5,795 | | UI in the past month | Parkinson | 1.46 (0.75; 2.86)
Fultz, 1999 ^357^ | >70 | Severe ≥21 days/month | Stroke (ever) | 1.85 (1.44; 2.37)
N = 3,991
Finkelstein, 2002 ^145^ | ≥30 | As diagnosed by a health professional | Back problems | 1.76 (1.33; 2.32)
N = 29,520
Landi, 2003 ^131^ | 79.5±9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | Hip Fracture | 1.26 (0.99; 1.59)
N = 3,194 | | 0 (complete control)-4 (inadequate control with multiple daily episodes) | Parkinson's disease | 0.99 (0.68; 1.43)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week, | Sensorial limitation vs. no | 1.9 (1.36; 2.65)
N = 3,804
Prevalent UI, Urge UI
Parazzini, 2003 ^138^ | >40 | UI in the past month | Neurological diseases | 2.1 (0.7; 5.9)
N = 2,205
Rohr, 2005 ^107^ | >45 | UI in the past month | Paraplegia | 1.8 (1.27; 2.53)
N = 5,795 | | UI in the past month | Parkinson | 1.66 (0.81; 3.39)
| | UI in the past month | Stroke | 1.84 (1.2; 2.8)
Prevalent UI, Stress UI
Parazzini, 2003 ^138^ | >40 | UI in the past month | Neurological diseases | 0.3 (0.04; 2.3)
N = 2,205
Rohr, 2005 ^107^ | >45 | UI in the past month | Paraplegia | 1.29 (0.93; 1.8)
N = 5,795 | | UI in the past month | Parkinson | 1.89 (0.97; 3.71)
| | UI in the past month | Stroke | 1.8 (1.19; 2.72)

Bold- significant association at 95% confidence level

Table F26 Association between health status, comorbidities, and UI in women

Author, Sample | Age | Definition of UI | Health Condition | Odds Ratio (95%CI)
Comorbidity, Incident UI
Ostbye, 2004 ^28^ | >65 | UI In the last 12 months | Arthritis | 1.18 (0.94; 1.49)
N = 5,322 | | | Kidney | 1.69 (1.22; 2.33)
| | | Foot and ankle trouble | 1.36 (1.04; 1.78)
Comorbidity, Prevalent UI
Parazzini, 2003 ^138^ | >40 | UI in the past month | Chronic obstructive pulmonary disease | 1.9 (1.3; 2.6)
N = 2,205
Kuh, 1999 ^179^ | 48 | UI at least two hourly during the day and at least twice a night | GP consultations High vs. low | 1.8 (1.1; 2.9)
N =1,333 | | Stress UI at least two hourly during the day and at least twice a night | GP consultations High vs. low | 1.4 (1; 1.9)
Nuotio, 2003 ^136^ | >70 | Stress UI, ever | Comorbidity (3 diseases) vs. <3 | 1.4 (0.7; 2.9)
N = 227
Parazzini, 2003 ^138^ | >40 | Stress UI, within the past month | Chronic obstructive pulmonary disease | 1.4 (0.8; 2.2)
N =2,205
Jackson, 2004 ^21^ | 70–79 | Stress UI, within the past week | Chronic obstructive pulmonary disease | 5.55 (1.33; 23.2)
N = 1,584
Rohr, 2005 ^107^ | >45 | Stress UI, within the past month | Chronic lung disease | 1.65 (1.35; 2.02)
N = 5,795
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a month | 1 disease | 1.85 (0.98; 3.49)
N = 3,804 | | | ≥2 diseases | 4.38 (2.5; 7.68)
Brown, 1996 ^194^ | 69–101 | UI daily | Chronic obstructive pulmonary disease vs. none | 1.4 (1.1; 1.9)
N = 7,949
Maclennan, 2000 ^84^ | 15–97 | UI within the past year | Most/ every day vs. never/occasionally | 1.6 (1.1; 2.3)
N = 3,010
Maggi, 2001 ^158^ | >65 | UI at least once per week | COPD | 1.53 (1.11; 2.12)
N = 1,531 | | | Hip fracture | 1.38 (1.02; 1.88)
| | | Night awakening | 1.48 (1.11; 1.97)
Finkelstein, 2002 ^145^ | ≥30 | UI diagnosed by a health professional | COPD | 1.35 (0.88; 2.07)
N = 29,520
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | 1 disease | 1.73 (0.97; 3.07)
N = 3,804 | | | ≥2 diseases | 5.93 (3.67; 9.57)
Nygaard, 2003 ^79^ | 50–69 | Mild-moderate: UI ≤15/days in the last month | Comorbidity index | 1.2 (1.02; 1.41)
N = 5,701 | | Severe: UI>15 days in the last month | Comorbidity index | 1.47 (1.16; 1.87)
Oskay, 2005 ^111^ | >50 | UI in the last month | Chronic illness | 1.95 (1.31; 2.91)
N = 500
Melville, 2005 ^112^ | 30–90 | UI at least monthly | Medical comorbidity score | 1.34 (1.1; 1.6)
N = 3,596 | 30–90 | Severity index score of 6–8 | Upper half of RxRisk score | 1.4 (1.1; 1.8)
Ostbye, 2004 ^28^ | >65 | UI in the last 12 months | Arthritis | 1.32 (1.08; 1.61)
N = 5,322 | | | Kidney | 3.36 (2.69; 4.21)
| | | Foot and ankle trouble | 1.25 (0.89; 1.76)
Kocak, 2005 ^368^ | ≥18 | UI once a week or less | Other chronic diseases | 1.2 (0.6; 2)
N = 1,012
Rohr, 2005 ^107^ | >45 | UI in the past month | Chronic lung disease | 1.66 (1.37; 2.01)
N = 5,795
Swanson, 2005 ^106^ | 45–81 | UI in the past month | Cough | 2.9 (1.7; 5)
N = 606 | | | Headaches | 1.5 (1; 2.3)
| | | Swollen ankles | 1.9 (1.2; 3.2)
| | | Usually have a cough | 3.5 (1.8; 6.8)
Kuh, 1999 ^179^ | 48 | Urge UI, ≥2/hourl during the day and at ≥2/night | GP consultations High vs. low | 1.1 (0.81; 1.6)
N =1,333
Parazzini, 2003 ^138^ | >40 | Urge UI, within the past month | Chronic obstructive pulmonary disease | 1.5 (0.9; 2.5)
N = 2,205
Rohr, 2005 ^107^ | >45 | Urge UI, within the past month | Chronic lung disease | 1.73 (1.4; 2.15)
N = 5,795
Health status, Incident UI
Jackson, 2004 ^21^ | 70–79 | At least weekly | Health ABC Performance score | 1.6 (1.1; 2.3)
N = 1,584
(Waetjen, 2007 ^49^ | 42–52 | UI: >weekly/daily | Health status Fair to poor vs. good to excellent | 2.99 (1.35; 6.62)
N = 3,302 | | Urge UI, frequency: at least monthly | Health status Fair to poor vs. good to excellent | 0.42 (0.18; 0.99)
Health status, Prevalent UI
Brown, 1999 ^353^ | Mean: 67 (SD: 7) | Mixed UI within the past week | Poor health | 1.43 (1.14; 1.79)
N = 2,763 | | Stress UI, within the past week | Poor health | 1.06 (0.78; 1.45)
Jackson, 2004 ^21^ | 70–79 | Stress UI, within the past week | Poor health | 1.6 (0.92; 2.78)
N = 1,584
McGrother, 2006 ^6^ | >40 | Stress UI, monthly or more | Health status Good vs. excellent | 1.3 (0.9; 1.8)
N = 12,570 | | Stress UI, monthly or more | Health status fair vs. excellent | 1.2 (0.7; 1.9)
| | Stress UI, monthly or more | Health status poor vs. excellent | 2 (0.9; 4.2)
| | Stress UI, monthly or more | Long-term illness | 0.6 (0.3; 1)
Huang, 2006 ^70^ | 40–69 | Stress UI, at least weekly incontinence (recall # of episodes in past week) | Poor/fair health in White women | 2.6 (1.43; 4.72)
N = 345
Brown, 1996 ^194^ | 69–101 | Daily | Poor overall health vs. good overall health | 1.6 (1.3; 2.1)
N = 7,949
Muscatello, 2001 ^160^ | >16 | >1 symptom: nocturia, urgency, stress UI, urge UI | Good health vs. excellent | 1.3 (0.6; 2.6)
N = 262 | | >1 symptom: nocturia, urgency, stress UI, urge UI | Faire or poor health vs. excellent | 2.9 (1.1; 7.4)
Brown, 1999 ^353^ | Mean: 67 (SD: 7) | Urge UI, within the past week | Poor health | 0.93 (0.69; 1.24)
N = 2,763
Kok, 1992 ^202^ | ≥60 | At least twice a week | poor mobility | 4.74 (2.55; 8.83)
N = 719
Heart diseases, Prevalent UI
Brown, 1996 ^194^ | 69–101 | Daily | congestive heart failure vs. none | 1.1 (0.8; 1.6)
N = 7,949
Schmidbauer, 2001 ^62^ | ≥20 | Within the past 4 weeks | SBP, 146+ vs. <=145 | 1.25 (1.02; 1.54)
N = 1,262 | ≥20 | Within the past 4 weeks | DBP, 91+ vs. <=90 | 1.17 (0.92; 1.48)
Finkelstein, 2002 ^145^ | ≥30 | As diagnosed by a health professional | Heart problems | 0.87 (0.48; 1.61)
N = 29,520 | ≥30 | As diagnosed by a health professional | Hypertension | 0.75 (0.48; 1.18)
Chen, 2003 ^123^ | >20 | Stress UI, within the past 2 weeks | Hypertension | 1.6 (0.7; 3.7)
N = 1,247
Landi, 2003 ^131^ | 79.5+- 9.5 | 0 (complete control)-4 (inadequate control with multiple daily episodes) | Atrial Fibrillation | 0.95 (0.72; 1.24)
N = 3,194 | | 0 (complete control)-4 (inadequate control with multiple daily episodes) | Heart Failure | 0.98 (0.78; 1.24)
Kocak, 2005 ^368^ | ≥18 | UI once a week or less | Hypertension | 2.9 (1.3; 6.3)
N = 1,012
Rohr, 2005 ^107^ | >45 | UI in the past month | Myocardial infarction | 0.96 (0.64; 1.45)
N = 5,795 | | Stress UI, within the past month | Myocardial infarction | 0.81 (0.51; 1.29)
| | Urge UI, within the past month | Myocardial infarction | 1.13 (0.72; 1.78)

Bold- significant association at 95% confidence level

Table F27 Association between gastrointestinal symptoms, surgery, and UI in females

Author, Sample | Age | Definition of UI | Risk Factors | OR(95%CI)
Prevalent UI, Constipation
Chiarelli, 1999 ^173^ | 18–23 | UI in the last year | Constipation, Rarely vs. never | 2.13 (1.87; 2.42)
N = 41,724 | | | Constipation, Sometimes vs. never | 2.86 (2.43; 3.36)
| | | Constipation, Often vs. never | 2.66 (2.07; 3.4)
| | | Constipation, Rarely vs. never | 2.46 (2.24; 2.71)
| | | Constipation, Sometimes vs. never | 2.16 (1.94; 2.4)
| | | Constipation, Often vs. never | 2.31 (1.96; 2.72)
| | | Constipation, Rarely vs. never | 2.67 (2.38; 2.99)
| | | Constipation, Sometimes vs. never | 2.05 (1.82; 2.31)
| | | Constipation, Often vs. never | 2.21 (1.87; 2.61)
Ueda, 2000 ^172^ | 40–75 | UI Sometimes | Constipation, Yes vs. no | 0.896 (0.642; 1.25)
N = 968
Landi, 2003 ^131^ | 79.5+-9.5 | UI weekly | Constipation, yes vs. no | 1.19 (0.95; 1.48)
N = 3,194
Oskay, 2005 ^111^ | >50 | UI weekly | Constipation, yes vs. no | 1.75 (1.17; 2.65)
N = 500
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Constipation, yes vs. no | 1 (0.8; 1.3)
N = 1,017 | | Severe: Sandvik score of 6–8 over the past year | Constipation, yes vs. no | 1.5 (1; 2.2)
Prevalent UI, Gastrointestinal Symptoms
Uusta-Fornel, 2004 ^208^ | 40 yr and 60 yr | UI weekly or more often | Digitation by defecation | 1.8 (0.9; 3.6)
N = 1,336
Chiarelli, 1999 ^173^ | 18–23 | UI in the last year | Bowel problems Rarely vs. never | 1.97 (1.65; 2.35)
N = 41,724 | | | Bowel problems Sometimes vs. never | 1.5 (1.18; 1.89)
| | | Bowel problems Often vs. never | 1.82 (1.33; 2.48)
| | | Bowel problems, Rarely vs. never | 1.66 (1.45; 1.91)
| | | Bowel problems, Sometimes vs. never | 1.69 (1.46; 1.96)
| | | Bowel problems, Often vs. never | 1.78 (1.42; 2.23)
| | | Bowel problems, Rarely vs. never | 1.48 (1.28; 1.72)
| | | Bowel problems, Sometimes vs. never | 1.39 (1.2; 1.62)
| | | Bowel problems, Often vs. never | 1.51 (1.22; 1.87)
Uusta-Fornel, 2004 ^208^ | 40 yr and 60 yr | Leakage weekly or more often | Groin hernia vs. none | 3.3 (0.7; 14.9)
N = 1,336
Prevalent UI, Surgery
Bortolotti, 2000 ^165^ | ≥40 | UI in the past year | Abdominal surgery | 1.2 (0.8; 1.7)
N = 2,767
Hvidman, 2003 ^356^ | 20–59 | UI in the past seven days | Ever abdominal or gynecologic operation | 1.7 (1.1; 2.8)
N = 3,900
Parazzini, 2003 ^138^ | >40 | UI in the past month | Abdominal surgery | 1 (0.7; 1.5)
N = 2,205 | | Stress UI in the past month | Abdominal surgery | 1.1 (0.8; 1.6)
| | Mixed UI in the past month | Abdominal surgery | 1 (0.8; 1.3)
Uustal Fornel, 2004 ^208^ | 40 yr and 60 yr | Leakage weekly or more often | Varicose vein surgery vs. none | 1.9 (1; 3.4)
N = 1,336
Fritel, 2005 ^110^ | 49–61 | Stress UI often or all of the time | Pelvic organ prolapse surgery | 1.5 (0.8; 2.7)
N = 2,625
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Bladder or urinary surgery | 1.2 (0.8; 1.9)
N = 1,017 | | Severe UI: Sandvik score of 6–8 over the past year | Bladder or urinary surgery | 1.4 (0.8; 2.4)
Prevalent UI, UI surgery
Schmidbauer, 2001 ^62^ | ≥20 | UI in the past 4 weeks | UI surgery | 1.43 (1.17; 1.75)
N = 1,262
Fritel, 2005 ^110^ | 49–61 | Stress UI often or all of the time | UI surgery | 1.1 (1.2; 3.7)
N = 2,625 | | | UI surgery | 1.3 (1.3; 4)
| | | UI surgery | 2.3 (1.4; 4)
Bortolotti, 2000 ^165^ | ≥40 | UI in the past year | Urological surgery | 1.9 (0.8; 4.6)
N = 2,767
Prevalent UI, UI during pregnancy
Foldspang, 1999 ^175^ | 20–59 | Stress UI in the past year | UI during pregnancy: | 3.4 (2.4; 4.6)
N = 4,710 | | | UI following childbirth: | 4.6 (3.5; 6)

Bold- significant association at 95% confidence level

Table F28 Association between pharmacological agents and UI in women

Author, Sample | Age | Definition of UI | Drug | OR(95%CI)
Incident UI
Jackson, 2004 ^22^ | 70–79 | UI at least weekly | Insulin | 3.5 (1.6; 7.9)
N = 1,584 | | UI at least weekly | Oral medications for diabetes | 1.8 (0.9; 3.7)
| | UI at least weekly | Not on medication for diabetes | 1 (0.5; 2)
Prevalent UI, Stress
Nuotio, 2003 ^136^ | >70 | UI ever | Polypharmacy (>3 drugs vs. <3) | 0.6 (0.3; 1.3)
N = 227 | | UI ever | Sleeping medication vs. none | 1.1 (0.6; 2.3)
Rohr, 2005 ^107^ | >45 | UI in the past month | Diuretics | 1.22 (1.06; 1.42)
N = 5,795
Prevalent UI, Total
Brown, 1996 ^194^ | 69–101 | UI daily | Non-thiazide diuretics vs. none | 1.2 (0.9; 1.6)
N = 7,949
Finkelstein, 2002 ^145^ | ≥30 | UI diagnosed by a health professional | Pain medication | 0.94 (0.68; 1.31)
N = 29,520 | | | Tranquilizers | 1.65 (1.06; 2.57)
| | | Antidepressants | 1.759 (1.04; 2.94)
| | | Hypnotics | 1.52 (1.07; 2.16)
| | | Narcotics | 1.37 (0.89; 2.13)
| | | Laxatives | 1.67 (1.18; 2.37)
| | | Asthma medication | 0.82 (0.51; 0.33)
| | | BP medication | 1.14 (0.7; 1.87)
| | | Heart medication | 0.99 (0.49; 2.02)
| | | Diuretics | 1.44 (0.96; 2.17)
| | | Antibiotics | 1.64 (1.25; 2.16)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week | Diuretics | 2.74 (1.63; 4.61)
N = 3,804
Moghaddas, 2005 ^359^ | 50–64 | UI, any leakage | Antidepressants | 1.32 (0.96; 1.81)
N = 6,642 | | UI, any leakage | Antidepressants In women with depression | 1.37 (0.97; 1.93)
Rohr, 2005 ^107^ | >45 | UI in the past month | Diuretics | 1.25 (1.09; 1.44)
N = 5,795
Nygaard, 2003 ^79^ | 50–69 | Mild-moderate incontinence - ≤15/days in the last month | Psychiatric medication | 1.55 (1.16; 2.07)
N = 5,701 | | Severe incontinence- >15 days in the last month | Psychiatric medication | 1.49 (1.01; 2.19)
Prevalent UI, Urge
Jackson, 2004 ^21^ | 70–79 | UI in the past week | Insulin | 1.78 (0.86; 3.68)
N = 1,584 | | | Oral medication | 1.02 (0.51; 2.04)
| | | Not on medication | 2.69 (1.37; 5.29)
Rohr, 2005 ^107^ | >45 | UI in the past month | Diuretics | 1.28 (1.1; 1.5)
N = 5,795

Bold- significant association at 95% confidence level

Table F29 Association between hormone use and UI in women

Author, Year, Sample | Age | Definition of UI | Hormone Use | Odds Ratio (95%CI)
Incident UI
Brown, 1996 ^194^ | 69–101 | UI daily | Oral estrogen vs. none | 1.9 (1.5; 2.4)
N = 7,949
Grodstein, 2004 ^16^ | 50–75 | Occasional: 1–3 times a month. | Dose of oral conjugated estrogen 0.3mg vs. none | 1.31 (1.13; 1.52)
N = 39,436 | | | Dose of oral conjugated estrogen 0.625mg vs. none | 1.47 (1.29; 1.46)
| | | Dose of oral conjugated estrogen1.25mg vs. none | 1.42 (1.25; 1.61)
| | | Oral estrogen alone or with progestin<1 year vs. never | 1.46 (1.16; 1.84)
| | | Oral estrogen alone or with progestin11.9 years vs. never | 1.71 (1.4; 2.08)
| | | Oral estrogen alone or with progestin24.9 years vs. never | 1.35 (1.22; 1.5)
| | | Oral estrogen alone or with progestin59.9 years vs. never | 1.41 (1.29; 1.54)
| | | Oral estrogen alone or with progestin>10 years vs. never | 1.56 (1.44; 1.69)
| | | Transdermal estrogen alone or with progestin<1 year vs. never | 1.76 (0.79; 3.91)
| | | Transdermal estrogen alone or with progestin11.9 years vs. never | 2.02 (1.01; 4.05)
| | | Transdermal estrogen alone or with progestin24.9 years vs. never | 1.99 (1.51; 2.62)
| | | Transdermal estrogen alone or with progestin59.9 years vs. never | 1.35 (1.08; 1.7)
| | | Transdermal estrogen alone or with progestin>10 years vs. never | 1.56 (1.2; 2.03)
| | | Duration of past use<2 years vs. never | 1.17 (1.06; 1.28)
| | | Duration of past use25 years vs. never | 1.19 (1.07; 1.33)
| | | Duration of past use69 years vs. never | 1.1 (0.97; 1.25)
| | | Duration of past use>10 years vs. never | 1.16 (0.98; 1.36)
| | | Time since last use<2 years vs. never | 1.39 (1.22; 1.58)
| | | Time since last use25 years vs. never | 1.24 (1.09; 1.4)
| | | Time since last use69 years vs. never | 1.18 (1.05; 1.34)
| | | Time since last use >10 years vs. never | 1.02 (0.91; 1.14)
| | | Oral estrogen alone vs. never | 1.45 (1.33; 1.57)
| | | Transdermal estrogen alone vs. never | 1.55 (1.29; 1.87)
| | | Oral estrogen and progestin vs. never | 1.47 (1.36; 1.59)
| | | Transdermal estrogen and progestin vs. never | 1.6 (1.27; 2.02)
| | | Past hormone use vs. never | 1.14 (1.06; 1.23)
Jackson, 2004 ^22^ | 70–79 | UI at least weekly | Current estrogen use vs. none | 1.7 (1.1; 2.6)
N = 1,584
Miller, 2003 ^134^ | 21–79 | even a small amount of urine in the previous month | Ever used HRT | 1.66 (1.11; 2.47)
N = 1,500
Jackson, 2004 ^21^ | 70–79 | Stress UI in the past week | Current estrogen use | 1.98 (1.26; 3.11)
N = 1,584
Thom, 1997 ^193^ | ≥60 | UI within the past year | ever used estrogen replacement therapy vs. never | 1.92 (1.33; 2.76)
N = 933 | | UI within the past year | ever used estrogen replacement therapy vs. never | 1.78 (1.13; 2.8)
Van Oyen, 2002 ^157^ | ≥15 | UI at least once a week, at least once a month, less than once a month | postmenopausal hormones | 1.67 (1.1; 2.55)
N = 3,804
Hvidman, 2003 ^356^ | 20–59 | UI within the past seven days | Present hormone use vs. none | 1.3 (0.7; 2.1)
N = 3,900 | | | Present hormone use indication, contraception vs. none | 1.4 (0.7; 2.5)
| | | Present hormone use indication, menstrual disorder vs. none | 2.9 (1.3; 6.5)
| | | Present hormone use indication, Menopause vs. none | 0.7 (0.1; 5.6)
| | | Present hormone use indication, Not specified vs. none | 1 (0.2; 4.2)
| | | Hormone use 1997 vs. none | 1 (0.6; 1.7)
| | | Hormone use 1997 indication, contraception vs. none | 1.1 (0.6; 2)
| | | Hormone use 1997 indication, menstrual disorder vs. none | 2.5 (1.1; 5.6)
| | | Hormone use 1997 indication, menopause vs. none | 0.7 (0.1; 5.6)
| | | Hormone use 1997 indication, not specified vs. none | 0.7 (0.2; 2.8)
| | | Hormone use ever vs. never | 0.9 (0.5; 1.5)
| | | Hormone use ever Indication, contraception vs. never | 1 (0.6; 1.7)
| | | Hormone use ever indication, menstrual disorder vs. never | 2 (1.2; 3.5)
| | | Hormone use ever indication, menopause vs. never | 0.6 (0.1; 4.7)
| | | Hormone use ever indication, urinary incontinence vs. never | 6.1 (0.6; 61.8)
| | | Hormone use ever indication, not specified vs. never | 1.1 (0.5; 2.4)
Teleman, 2004 ^360^ | 50–59 | At least occasionally | HRT use | 1.5 (1.2; 1.8)
N = 2,682
Moghaddas, 2005 ^359^ | 50–64 | Any leakage | Oral contraceptives, ever | 1.15 (1; 1.31)
N = 6,642 | | | Peri- or postmenopausal women with current systemic hormone therapy use in the hormonal status | 1.11 (0.98; 1.27)
| | | Oral contraceptives, ever; Women with depression | 1.18 (0.98; 1.42)
| | | Peri- or postmenopausal women with current Women with depression Systemic hormone therapy use in the hormonal status | 1 (0.84; 1.18)
| | | Oral contraceptives, ever | 1.12 (0.92; 1.36)
| | | Peri- or postmenopausal women with current systemic hormone therapy use in the hormonal status | 1.29 (1.1; 1.56)
Danforth, 2006 ^68^ | 25–54 | Occasional: 1–3/month. | Oral contraceptive use Former vs. never | 1.2 (1.1; 1.3)
N = 83,355 | | Occasional: 1–3/month. | Oral contraceptive use Current vs. never | 1 (1; 1.1)
| | Frequent: At least weekly. | Oral contraceptive use Former vs. never | 1.2 (1.15; 1.3)
| | Frequent: At least weekly. | Oral contraceptive use Current vs. never | 1.1 (1.1; 1.2)
| | Severe: Wet underwear. | Oral contraceptive use Former vs. never | 1.2 (1.1; 1.3)
| | Severe: Wet underwear. | Oral contraceptive use Current vs. never | 1 (0.9; 1.1)
Jackson, 2006 ^100^ | 55–75 | Any leakage in the past year | Oral estrogen use in past month | 1.2 (0.9; 1.5)
N = 1,017 | | Any leakage in the past year | Estrogen cream past month | 2.8 (1.5; 2.4)
| | Severe: Sandvik score of 6– 8 over the past year | Oral estrogen use in past month | 1.6 (1.1; 2.3)
| | Severe: Sandvik score of 6–8 over the past year | Estrogen cream past month | 0.9 (0.4; 2.1)
Brown, 1996 ^194^ | 69–101 | Daily | Oral estrogen vs. none | 1.9 (1.5; 2.4)
N = 7,949
Jackson, 2004 ^21^ | 70–79 | Urge UI: within the past week | Current estrogen use | 1.68 (1.07; 2.63)
N = 1,584
Huang, 2006 ^70^ | 40–69 | Urge UI: at least weekly incontinence to recall the number of episodes in the past 7 days | Oral estrogen use | 1.82 (1.12; 2.93)
N = 345 Asian women

Table F30 Prevalence of UI among males with risk factors

Author Sample | Risk factor | UI | %
Diokno, 1990 ^314^ | Arthritis | UI | 50.40
N = 651 | | Urge | 43.20
| | Stress | 45.50
| Cardiovascular problems | UI | 6.90
| | Urge | 2.30
| | Stress | 10.00
| Stroke | UI | 10.10
| | Urge | 7.70
| | Stress | 9.10
| Mobility Problems | UI | 14.70
| | Urge | 11.30
| | Stress | 0.00
| Hearing and vision problems | UI | 38.60
| | Urge | 34.90
| | Stress | 27.30
| Any vision problems | UI | 28.80
| | Urge | 15.60
| | Stress | 20.00
| Diabetes | UI | 20.30
| | Urge | 20.00
| | Stress | 36.40
| Pulmonary problems | UI | 15.70
| | Urge | 26.70
| | Stress | 9.10
| Bowel problems | UI | 11.20
| | Urge | 11.10
| | Stress | 9.10
| Genital surgery | UI | 44.00
| | Urge | 26.70
| | Stress | 45.50
| UTI | UI | 13.40
| | Urge | 9.60
| | Stress | 27.30
Smoger, 2000 ^169^ | Diuretics | UI | 35.60
N = 809 | Antispasmodic agents | UI | 60.00
| Prostate active agents | UI | 38.10
| Bladder surgery | UI | 58.30
| Prostate surgery | UI | 46.60
Van Kampen, 1997 ^369^ | Transurethral resection of prostate | UI | 19
N = 216 | 1 year after transurethral resection | UI | 1.50
Van Kampen, 1997 ^369^ | Transvesical prostatectomy for benign prostatic hyperplasia | UI | 15.00
N = 298 | 1 years after transvesical prostatectomy for benign prostatic hyperplasia | UI | 1.00

Table F31 Prevalence and incidence of UI in males with prostate cancer

Author Sample | Patient Population | UI | N | %
Lee, 1996 ^370^ | Prostate cancer with no history of prior transurethral resection of the prostate | UI | 626 | 0.20
Talcott, 1998 ^184^ | Localized prostate cancer | | 279 | 2.00
Adolfsson, 1998 ^252^ | Prostate cancer | UI | 342 | 30.00
| Men not reporting any treatment for prostate cancer 22 months after diagnosis | UI | 139 | 30.00
Joly, 1998 ^316^ | Localized prostate cancer | UI | 71 | 9.00
Smoger, 2000 ^169^ | Prostate cancer | UI | 809 | 43.50
Augustin, 2002 ^371^ | Prostate cancer | UI | 368 | 6
Liu, 2005 ^372^ | Prostate cancer | UI | 1,192 | 2.9
| Prostate cancer with prior transurethral resection of the prostate | | 1,192 | 7.8
Jacobsen 2007 ^47^ | Prostate cancer | pad weight gain > 8 gm/24h ours | 148 | 4.1
| | | 29 | 0
| | | 28 | 7.4
| Localized prostate cancer | UI | 172 | 4
| | | 67 | 3.5
Johnson, 2004 ^23^ | non-Hispanic Whites with prostate cancer | Occasional leakage | 1,475 | 8.8
| non-Hispanic Whites with prostate cancer | Frequent leakage | 1,475 | 2.1
| African-American with prostate cancer | Occasional leakage | 321 | 9.5
| African-American with prostate cancer | Frequent leakage | 321 | 2
| Hispanic with prostate cancer | Occasional leakage | 279 | 11.2
| Hispanic with prostate cancer | Frequent leakage | 279 | 6.5
Lee, 1996 ^370^ | Prostate cancer with history of prior transurethral resection of the prostate | UI | 132 | 2.00
Sandhu, 2000 ^373^ | Prostate cancer patients with a prior history of a transurethral resection of the prostate | incident stress UI with 1 pad daily or occasional leakage | 120 | 8.00

Table F32 Prevalence or incidence of UI after treatments for prostate cancer

Author | Treatment | UI | N | %
Radical prostatectomy
Talcott, 1998 ^184^ | 3 months after prostatectomy for localized prostate cancer | Pad use | 125 | 58.00
| 1 year after prostatectomy for localized prostate cancer | | 125 | 35.00
Adolfsson, 1998 ^252^ | 22 months after radical prostatectomy | UI | 22 | 65.00
Van Kampen, 1997 ^369^ | Radical prostatectomy for localized prostate cancer | UI | 175 | 66.00
| 1 year after radical prostatectomy for localized prostate cancer | | 175 | 2.00
Goluboff, 1998 ^313^ | 3.3 years after radical retropubic prostatectomy | regular use of pads | 480 | 8.2
| 6 months after radical retropubic prostatectomy | | 480 | 8.00
Gray, 1999 ^374^ | 2.7 years after Perineal radical prostatectomy | Wears >2 pads/day | 23 | 22.00
| | Must wear pads at all times | 23 | 26.00
| | Leak with minimal effort | 23 | 13.00
| | Pads are completely soaked | 6 | 17.00
| 2.7 years after retropubic radical prostatectomy | Wears .2 pads/day | 49 | 22.00
| | Must wear pads at all times | 49 | 35.00
| | Leak with minimal effort | 49 | 18.00
| | Pads are completely soaked | 24 | 17.00
| 2.7 years after radical prostatectomy | UI | 209 | 43.00
Catalona, 1999 ^375^ | 18 months after retropubic prostatectomy | UI | 1,325 | 8.00
Augustin, 2002 ^371^ | 12 months after radical retropubic prostatectomy | protection against urinary incontinence | 368 | 27.2
| | one pad per day | 368 | 14.7
| | two or more pads per day | 368 | 12.5
| | surgical treatment for incontinence | 368 | 1.4
Sebesta, 2002 ^152^ | younger than 65 years of age 18 months after radical prostatectomy | UI | 674 | 56.3
| | Several episodes per week | 674 | 10.8
| | <1/day | 674 | 19.4
| | 1/day | 674 | 16.8
| | >1/day | 674 | 9.2
| | Pad use 0–1/day | 674 | 12.9
| | Pad use 1–2/day | 674 | 8.9
| | Pad use 2–3/day | 674 | 3.7
| | Pad use 3–4/day | 674 | 2.5
| | Pad use >4/day | 674 | 2.7
| | Sudden urge/no time | 674 | 17.4
| | Physical exertion | 674 | 50.8
| | Urge incontinence only (no stress | 674 | 5.2
| | While in bed/running to bathroom | 674 | 7.6
| | Dry in AM/Leak only in PM | 674 | 13.4
Hu, 2003 ^32^ | Radical prostatectomy, 1991 | UI | 12,079 | 20
| Radical prostatectomy, 1992 | | 12,079 | 25
| Radical prostatectomy, 1993 | | 12,079 | 19
| Radical prostatectomy, 1994 | | 12,079 | 11
| Radical prostatectomy, 1995 | | 12,079 | 4
| Age 65–69,Radical prostatectomy, 1991 | | 12,079 | 23
| Age 65–69,Radical prostatectomy, 1992 | | 12,079 | 24
| Age 65–69,Radical prostatectomy, 1993 | | 12,079 | 20
| Age 65–69,Radical prostatectomy, 1994 | | 12,079 | 10
| Age 65–69,Radical prostatectomy, 1995 | | 12,079 | 4
| Age 70–74,Radical prostatectomy, 1991 | | 12,079 | 19
| Age 70–74,Radical prostatectomy, 1992 | | 12,079 | 25
| Age 70–74,Radical prostatectomy, 1993 | | 12,079 | 18
| Age 70–74,Radical prostatectomy, 1994 | | 12,079 | 11
| Age 70–74,Radical prostatectomy, 1995 | | 12,079 | 4
| Age >75,Radical prostatectomy, 1991 | | 12,079 | 19
| Age >75,Radical prostatectomy, 1992 | | 12,079 | 26
| Age >75,Radical prostatectomy, 1993 | | 12,079 | 19
| Age >75,Radical prostatectomy, 1994 | | 12,079 | 11
| Age >75,Radical prostatectomy, 1995 | | 12,079 | 8
Maffezzini, 2003 ^132^ | 29 months after radical retropubic prostatectomy for clinically intracapsular prostate cancer | stress UI requiring 1–3 pads/day | 295 | 8.8
| 29 months after radical retropubic prostatectomy for clinically intracapsular prostate cancer | UI, >4 pads/day | 295 | 2.3
Hisasue, 2004 ^376^ | 12 months after radical retropubic prostatectomy | stress UI | 300 | 4.3
Jacobsen | 3 months after Radical prostatectomy | pad weight gain of more than 8 gm during a 24- hour period | 148 | 42
| 12 months after Radical prostatectomy | pad weight gain of more than 8 gm during a 24- hour period | 148 | 12.8
| 3 months after open retropubic prostatectomy | UI | 172 | 42
| 12 months after open retropubic prostatectomy | UI | 172 | 12.8
Johnson, 2004 ^23^ | 12 Months after radical prostatectomy for non-Hispanic whites with prostate cancer | Occasional leakage | 1,475 | 50.2
| 12 Months after radical prostatectomy for non-Hispanic whites with prostate cancer | Frequent leakage | 1,475 | 15.6
| 12 Months after radical prostatectomy for African-American with prostate cancer | Occasional leakage | 321 | 51.4
| 12 Months after radical prostatectomy for African-American with prostate cancer | Frequent leakage | 321 | 9
| 12 Months after radical prostatectomy for Hispanic with prostate cancer | Occasional leakage | 279 | 46.9
| 12 Months after radical prostatectomy for Hispanic with prostate cancer | Frequent leakage | 279 | 14.9
| 60 Months after radical prostatectomy for non-Hispanic whites with prostate cancer | Occasional leakage | 1,475 | 53.7
| 60 Months after radical prostatectomy for non-Hispanic whites with prostate cancer | Frequent leakage | 1,475 | 14.3
| 60 Months after radical prostatectomy for African-American with prostate cancer | Occasional leakage | 321 | 39.7
| 60 Months after radical prostatectomy for African-American with prostate cancer | Frequent leakage | 321 | 10.4
| 60 Months after radical prostatectomy for Hispanic with prostate cancer | Occasional leakage | 279 | 47.4
| 60 Months after radical prostatectomy for Hispanic with prostate cancer | Frequent leakage | 279 | 18.7
Laparoscopic radical prostatectomy
Olson, 2001 ^377^ | 1 month after laparoscopic radical prostatectomy for clinically localized prostate cancer | Incident UI | 101 | 90.10
| 3 months after laparoscopic radical prostatectomy for clinically localized prostate cancer | | 77 | 71.40
| 6 months after laparoscopic radical prostatectomy for clinically localized prostate cancer | | 61 | 42.60
| 12 months after laparoscopic radical prostatectomy for clinically localized prostate cancer | | 37 | 43.2
| 1 months after laparoscopic radical prostatectomy for clinically localized prostate cancer | Daily pad use, >1/day | 78 | 22.8
| 3 months after laparoscopic radical 3 months after laparoscopic radical prostatectomy for clinically localized prostate cancer | | 61 | 20.8
Jacobsen, 2007 ^47^ | 3 months after Laparoscopic prostatectomy (first half procedures) | pad weight gain > 8 gm/24-hour | 29 | 70.4
| 12 months after Laparoscopic prostatectomy (first half procedures) | | 29 | 20.72
| 3 months after Laparoscopic prostatectomy (last half procedures) | | 28 | 60
| 12 months after Laparoscopic prostatectomy (last half procedures) | | 28 | 14.3
| 3 months after laparoscopic prostatectomy (second half) | UI | 67 | 60
| 3 months after laparoscopic prostatectomy (first half) | | 67 | 70.4
| 12 months after laparoscopic prostatectomy (second half) | | 67 | 19.2
| 12 months after laparoscopic prostatectomy (first half) | | 67 | 16
Radiation for prostate cancer
Lee, 1996 ^370^ | More than 3 months after prostate cancer treated with definitive external-beam radiation therapy | Incident late grade 2 or higher urinary incontinence | 758 | 0.50
| 5 years after definitive external-beam radiation therapy for prostate cancer | actuarial urinary incontinence rate | 758 | 1.30
Talcott, 1998 ^184^ | 3 months after radiotherapy for localized prostate cancer | Pad use | 135 | 5.00
| 1 year after radiotherapy for localized prostate cancer | | 135 | 5.00
Adolfsson, 1998 ^252^ | 22 months after External radiation | UI | 37 | 33.00
Joly, 1998 ^316^ | 4–8 years after external beam irradiation and brachytherapy | UI | 65 | 40.00
| 4–8 years after external beam irradiation and brachytherapy | invaliding UI | 65 | 9.00
| 4–8 years after external beam irradiation and brachytherapy | diagnosed UI (charts) | 65 | 11.00
Sandhu, 2000 ^373^ | 5 years after radiation with acute >/= Grade 2 GU symptoms | incident stress incontinence requiring 1 pad daily for protection or experienced occasional leakage | 110 | 18.00
| 5 years after radiation with Grade 1 or no acute urinary symptoms | | 110 | 7.00
Liu, 2005 ^372^ | 54 months after external beam radiotherapy | Incident Grade 1 incontinence | 1,192 | 4.9
| | Incident Grade 2 incontinence | 1,192 | 0.6
| | Incident Grade 3 incontinence | 1,192 | 0.6
Sandhu, 2000 ^373^ | 5 years after high-dose 3-dimensional conformal radiotherapy in patients with a prior history of a transurethral resection of the prostate | incident stress incontinence requiring 1 pad daily for protection or experienced occasional leakage | 110 | 9.00
Adolfsson, 1998 ^252^ | 22 months after endocrine treatment | UI | 109 | 24.00
| 22 months after endocrine treatment subsequent to external or radical prostatectomy | | 35 | 20.00
Fowler, 1996 ^378^ | 3–5 years after high energy external beam radiation therapy | Dripping or leaking urine | 621 | 29

Table F33 Prevalence and severity of post-prostatectomy UI

Author | Country | Method | UI Definition | Surgical Procedure(s) | Response Rate | Number | Followup (Months) | UI Prevalence (%)
Ramon, 1993 ^379^ | France | Clinical evaluation | Stress UI | RRP | 6 Months: 100% | 6 Months: 484 | 6, 12 | 6 Months: 10%
| | | | | 12 Months: 82% | 12 Months: 398 | | 12 Months: 5%
Lowe, 1996 ^380^ | USA | Patient interviews and questionnaires | Any loss of urinary control requiring protection | RRP | 91% | 188 | 1, 3, 6, 12 | 1 Month: 83%
| | | | | | | | 3 Months: 49%
| | | | | | | | 6 Months: 26.5%
| | | | | | | | 12 Months: 16%
| | | | | | | | >12 Months: 11.7%
Weldon, 1997 ^381^ | USA | Prospective clinical evaluation | Daily pad use | RPP | Not reported | 220 | 18 | 5%
Bishoff, 1998 ^382^ | USA | Mailed survey | Any UI | RRP and RPP | 80% RRP | 784 RRP | ≥12 | Immediate post-op
| | | Pad use | | 78% RPP | 123 RPP | | 79% RPP
| | | | | | | | 85% RRP
| | | | | | | | Pad use:
| | | | | | | | 39% RPP
| | | | | | | | 56% RRP
Goluboff, 1998 ^313^ | USA | Mailed survey | Any UI | RRP | 78.2% | 480 | Mean: 39 | 8.2%
| | | Daily or pad use | | | | Range: 1 – 8.8 years | 7.4% daily
| | | Continuous UI | | | | | 0.8% continuous
| | | | | | | | 43.6% UUI
Catalona, 1999 ^375^ | USA | Self-reported questionnaire. | Requiring protection to keep outer garments dry. | RRP | 70.9% | 1,325 | Minimum of 18 | 8%
Gray, 1999 ^374^ | USA | Mailed survey | Pad use | RRP | 80% | RRP: 96 | Median: 32 | RPP:
| | | Incontinence more than once per week | RPP | | RPP: 71 | Range: 4 – 65 | <1 year: 50%
| | | | | | | | 1–2 years: 26%
| | | | | | | | >2 years: 28%
| | | | | | | | RRP:
| | | | | | | | <1 year: 27%
| | | | | | | | 1–2 years: 26%
| | | | | | | | >2 years: 18%
Horie, 1999 ^383^ | Japan | Self reported at clinic visits | Pad use | RRP | 97% | 104 | 1, 3, 6, 12 | 22%
Benoit, 2000 ^384^ | USA | Review of Medicare records | Daily urinary leakage and pad use | RRP | 100% | 25,651 | 12 | 7.9%
Poon, 2000 ^385^ | USA | Self-reported telephone interviews | Pad use | RRP | 85% | 165 | 12 | 3–5%
Olsson, 2001 ^377^ | France | Self-reported questionnaires | Pad use | LRP | 1 Month: 44.3% | 228 | 12 | 22%
| | | | | 3 Months: 33.8%
| | | | | 6 Months: 26.8%
| | | | | 12 Months: 16.2%
Sebesta, 2002 ^152^ | USA (multiple states) | Mailed survey | Urine leakage in past week | RRP | 78% | 674 | Within 18 months of surgery | 56.3%
| | | | | | | | 10.8% several times/day
| | | | | | | | 19.4% <once/day
| | | | | | | | 16.8% once/day
| | | | | | | | 9.2% >once/day
Hu, 2003 ^32^ | USA | Data was taken from random sample of standard Medicare files. | Not reported. | RRP | Not reported | 12,079 | 36 | 20% in 1991
| | | Taken from Medicare data, definition of incontinence was not listed. | | | | | 4% in 1995
Maffezini, 2003 ^132^ | Italy | Consecutive series. | UI: Use of 4 or more pads/day | RRP | 98.3% | 300 | 29 | 11.1%
| | Data came from review of charts and records from patients. | SUI: Usually wore protection but less than 4 pads/day | | | | | 8.6% SUI
| | | | | | | | 2.3%
Moinzadeh ^386^ , 2003 | USA | Self-administered questionnaire and/or third party telephone interview | Pad use | RRP | 100% | 200 | 3, 6, 12, 15 | Baseline: 36.5%
| | | | | | | | 3 Months: 18%
| | | | | | | | 6 Months: 9%
| | | | | | | | 12 Months: 1.5%
| | | | | | | | 15 Months: 0.5%
Salomon, 2003 ^387^ | USA and France | Self-administered questionnaire | Pad use | RRP | 100% | 146 | 12 | 29.5%
Talcott, 2003 ^142^ | USA | Self-administered questionnaire | Frequency and magnitude of urine loss | RRP | 85.2% at 3 month followup | 613 | Baseline, 3 months, 1 and 2 years | 4.9% Baseline
| | | | | 76.6% for 24 months | | | 34.9% 3 months
| | | | | | | | 23.9% 1 year
| | | | | | | | 23.4% 2 years
Deliveliotis, 2004 ^15^ | Greece | Self-administered questionnaire | Daily urine leakage | 105 RRP | 73.9% RRP | 203 | 2 years | RRP: 9%
| | | | 98 TURP | 64.9% TURP | | | TURP: 2.8%
| | | | | 54.1% controls
Deliveoliotis, 2002 ^388^ | Greece | Self-administered questionnaire | Pad use | RRP | 100% | 149 | 3, 6, 9, 12 | 3 Months: 39.6%
| | | | | | | | 6 Months: 26.8%
| | | | | | | | 9 Months: 13.4%
| | | | | | | | 12 Months: 5%
Johnson, 2004 ^23^ | USA | Self-administered questionnaire | Self reported level of urinary control: total, occasional leakage, frequent leakage or no control, and unknown or missing. | RRP | 62.3% | 3,533 | Baseline, 6, 12, 24, and 60 months after prostate cancer diagnosis | Baseline:
| | | | | | | | 10.9% Whites (2.1% frequent)
| | | | | | | | 11.5% Blacks (2%)
| | | | | | | | 17.7% Hispanics (6.5% frequent)
| | | | | | | | 6 months:
| | | | | | | | 74.7% Whites (22.6% frequent)
| | | | | | | | 67.6% Blacks (23.4% frequent)
| | | | | | | | 67.5% Hispanics (26.7% frequent)
| | | | | | | | 12 months:
| | | | | | | | 65.8% Whites (15.6% frequent)
| | | | | | | | 60.4% Blacks (9% frequent)
| | | | | | | | 61.8% Hispanic (14.9% frequent)
| | | | | | | | 24 months:
| | | | | | | | 60.0% Whites (9.8% frequent)
| | | | | | | | 56.2% Blacks (11.1% frequent)
| | | | | | | | 64.3% Hispanics (11.3% frequent)
| | | | | | | | 60 months:
| | | | | | | | 68% Whites (14.3% frequent)
| | | | | | | | 50.1% Blacks (10.4% frequent)
| | | | | | | | 66.1% Hispanics (18.7% frequent)
Moore, 2007 ^389^ | Canada | Clinical evaluation | More than 8 grams of urine loss on 24 hour pad test | RRP | 93% | RRP: 198 | 3 and 12 | Baseline: 4%
| | | | Lap RRP | | Lap RRP: 48 | | 3 Months: 43%
| | | | | | | | 12 Months: 15%
Smither, 2007 ^48^ | USA | Prospective cohort with clinic evaluation. Chart reviews. | ≤1 gram of urine loss on a 1 hour pad test | RRP | 100% | 203 | 2, 6, 18, 30, 42, and 54 weeks post-procedure | Minimal ( ≤1 gm):
| | | | | | | | 3% 2 weeks
| | | | | | | | 37% 6 weeks
| | | | | | | | 66% 18 weeks
| | | | | | | | 85% 30 weeks
| | | | | | | | 87% 42 weeks
| | | | | | | | 91% 54 weeks
| | | | | | | | Mild (1.1–1.9 gms):
| | | | | | | | 23% 2 weeks
| | | | | | | | 23% 6 weeks
| | | | | | | | 22% 18 weeks
| | | | | | | | 9% 30 weeks
| | | | | | | | 8% 42 weeks
| | | | | | | | 5% 54 weeks
| | | | | | | | Moderate (10.0–49.9 gms):
| | | | | | | | 50% 2 weeks
| | | | | | | | 26% 6 weeks
| | | | | | | | 8% 18 weeks
| | | | | | | | 4% 30 weeks
| | | | | | | | 3% 42 weeks
| | | | | | | | 3% 54 weeks
| | | | | | | | Severe (≥50 gms)
| | | | | | | | 24% 2 weeks
| | | | | | | | 14% 6 weeks
| | | | | | | | 4% 18 weeks
| | | | | | | | 2% 30 weeks
| | | | | | | | 2% 42 weeks
| | | | | | | | 1% 54 weeks
Eastham, 1996 ^390^ | USA | Clinical evaluation and self-reported questionnaires | Leaking urine onto ≥1/pads daily, patients who were wet with normal activity | RRP | 95% | RRP: 191 | 1 Year and 2 year | RRP:
| | | | RRP (With new anastomic technique, 1990) | | RRP (Post 1990 w/new technique): 390 | | 1 year: 14% 2 years: 9%
| | | | | | | | RRP w/anastomic method):
| | | | | | | | 1 year: 8% 2 years: 5%
Begg, 2002 ^391^ | USA | Diagnostic tests | Leakage or absence of urinary control >2 times/day | RRP | 100% | 11,522 | >1 year | 65–69 years: 7%
| | | | | | | | 70–74 years: 7%
| | | | | | | | 75+ years: 9%
Stanford, 2000 ^392^ | USA | Mailed, self-reported questionnaires or telephone and in-person interviews | Leakage of urine | RRP | 62.3% | 3,533 | 12 months and 24 months | Baseline Age: <60:
| | | | | | | | Occasional leakage: 6.8%
| | | | | | | | Frequent leakage: 1.4%
| | | | | | | | No control: 0.9%
| | | | | | | | 60–64:
| | | | | | | | Occasional leakage: 9.8%
| | | | | | | | Frequent leakage: 1.8%
| | | | | | | | No control: 0%
| | | | | | | | 65–74:
| | | | | | | | Occasional leakage: 11.3%
| | | | | | | | Frequent leakage: 3.7%
| | | | | | | | No control: 1.3%
| | | | | | | | 75–79:
| | | | | | | | Occasional leakage: 9.6%
| | | | | | | | Frequent leakage: 4.0%
| | | | | | | | No control: 0%
| | | | | | | | 12 Months:
| | | | | | | | Age <60:
| | | | | | | | Occasional leakage: 48.5%
| | | | | | | | Frequent leakage: 7.0%
| | | | | | | | No control: 2.5%
| | | | | | | | 60–64:
| | | | | | | | Occasional leakage: 53.4%
| | | | | | | | Frequent leakage: 11.5%
| | | | | | | | No control: 4.0%
| | | | | | | | 65–74:
| | | | | | | | Occasional leakage: 47.6%
| | | | | | | | Frequent leakage: 16.2%
| | | | | | | | No control: 2.4%
| | | | | | | | 75–79:
| | | | | | | | Occasional leakage: 28.2%
| | | | | | | | Frequent leakage: 23.4%
| | | | | | | | No control: 13%
| | | | | | | | 24 Months:
| | | | | | | | Age <60:
| | | | | | | | Occasional leakage: 46.4%
| | | | | | | | Frequent leakage: 5.2%
| | | | | | | | No control: 0.7%
| | | | | | | | 60–64:
| | | | | | | | Occasional leakage: 55.8%
| | | | | | | | Frequent leakage: 6.6%
| | | | | | | | No control: 3.6%
| | | | | | | | 65–74:
| | | | | | | | Occasional leakage: 50.4%
| | | | | | | | Frequent leakage: 10.6%
| | | | | | | | No control: 0.9%
| | | | | | | | 75–79:
| | | | | | | | Occasional leakage: 11.1%
| | | | | | | | Frequent leakage: 27.0%
| | | | | | | | No control: 13.8%
Emberton, 1996 ^393^ | UK | Mailed, self-reported questionnaires | Leakage of urine | RRP | 82.4% | 4,226 | 3 Months | 3 Months:
| | | | | | | | “I leak a tiny amount:” 44.4
| | | | | | | | “Sufficient to cause a problem:” 6.1%
| | | | | | | | “Sufficient to need pads:” 4.4%
Fowler, 1995 ^394^ | USA | Self-reported mailed questionnaires and telephone interviews | Dripping or leaking urine over the past month | RRP | 92% | 1,072 | 2–4 years after surgery | “None now:” 15.9%
| | | | | | | | “Dripping now, no pad use:” 21.5%
| | | | | | | | “Wear pads or clamp:” 20.7%
Kundu, 2004 ^395^ | USA | Self-reported questionnaires | Use of pads or other protection | RRP | 78.7% | 2,737 | Minimum of 18 months | Younger than 50: 5%
| | | | | | | | 50–59: 4%
| | | | | | | | 60–69: 7%
| | | | | | | | 70+: 14%
Harris, 2003 ^396^ | USA | Surgeon evaluation | Pad usage | RPP | 100% | 508 | 1, 2, 4, 6, and 12 months | 1 month: 62%
| | | | | | | | 2 months: 47%
| | | | | | | | 4 months: 26%
| | | | | | | | 6 months: 15%
| | | | | | | | 12 months: 4%
Varkarakis, 2004 ^397^ | Austria | In person interviews | Pad usage | RRP | 84.9% | 526 | 1, 6, and 12 months | 3 months: 25.2%
| | | | | | | | 6 months: 18.3%
| | | | | | | | 12 months: 6.5%
Lepor, 2004 ^398^ | USA | Self-reported, mailed questionnaires | Pad usage | RRP | 94.2% | 500 | 3, 6, 12, and 24 months | 3 months: 29.1%
| | | | | | | | 6 months: 12.8%
| | | | | | | | 12 months: 7.9%
| | | | | | | | 24 months: 1.5%
Penson, 2005 ^399^ | USA | Self-reported questionnaires or telephone interviews | Leakage of urine | RRP | 62.3% | 3,533 | 6, 12, 24, and 60 months | 6 months:
| | | | | | | | Occasional leakage: 52%
| | | | | | | | Frequent leakage: 19%
| | | | | | | | No control: 6%
| | | | | | | | 12 months:
| | | | | | | | Occasional leakage: 49%
| | | | | | | | Frequent leakage: 13%
| | | | | | | | No control: 3%
| | | | | | | | 24 months:
| | | | | | | | Occasional leakage: 50%
| | | | | | | | Frequent leakage: 9%
| | | | | | | | No control: 2%
| | | | | | | | 60 months:
| | | | | | | | Occasional leakage: 51%
| | | | | | | | Frequent leakage: 11%
| | | | | | | | No control: 3%
Sacco, 2006 ^400^ | Italy | Telephone or in-person interviews | Pad usage | RRP | 86% | 985 | 3, 6, 12, and 24 months | 3 months: 31.8%
| | | | | | | | 6 months: 22%
| | | | | | | | 12 months: 13.1%
| | | | | | | | 24 months: 6.8%
Saranchuk, 2005 ^401^ | USA | Clinical database | Pad usage | RRP | 100% | 647 | 12 and 24 months | 12 months: 13%
| | | | | | | | 24 months: 7%
Van Randenborgh, 2004 ^402^ | Germany | Self-administered questionnaires | Pad usage | RRP | 100% | 1,013 | Up to 12 months | With Urethral Stump:
| | | | | | | | <4 weeks: 67%
| | | | | | | | 1–3 months: 51%
| | | | | | | | 3–6 months: 22%
| | | | | | | | 6–12 months: 0%
| | | | | | | | w/o Urethral Stump:
| | | | | | | | <4 weeks: 85%
| | | | | | | | 1–3 months: 56%
| | | | | | | | 3–6 months: 35%
| | | | | | | | 6–12 months: 95%
Mettlin, 1997 ^403^ | USA | Hospital cancer registries | Pad usage | RRP | 85.3% | 2,922 | Up to 5 years | Occasional, no pads required: 24.6%
| | | | | | | | Daily, <2 pads required: 11.7%
| | | | | | | | Daily, >2 pads required: 4.8%
| | | | | | | | Total incontinence: 2.9%

TURP: Transurethral retropubic prostatectomy; RRP= radical retropubic prostatectomy; RPP = radical perineal prostatectomy; Lap RRP = laproscopic retropubic prostatectomy; UI=urinary incontinence; SUI=stress urinary incontinence

Table F34 Association between race and FI

Author | Fecal Incontinence | Race, Population Groups | Odds Ratio (95%CI)
Sample
Women
Macarthur, 2005 ^404^ | Fecal incontinence | Asian vs. Non-Asian, 6 years postpartum | 3.42 (2.36; 4.94)*
N = 4,046 | Persistent fecal incontinence | Asian vs. Non-Asian, 6 years postpartum among primiparae at index delivery | 13.46 (5.88; 30.81)*
1,793 primiparae 3,813 included in the model | Persistent fecal incontinence | Asian vs. Non-Asian, 6 years postpartum | 6.00 (3.66; 9.86)*
MacArthur, 2001 ^405^ | Fecal incontinence | Asian vs. Non-Asian, 3 months postpartum | 3.21 (2.04; 5.05)*
N = 7,879
Richter, 2005 ^406^ | Anal incontinence | Non Whites vs. Whites with morbid obesity before laparoscopic weight loss surgery | 0.58 (0.28; 1.16)
N = 180
Nursing homes
Nelson 1998, ^306^ | Fecal incontinence | Non-Caucasian vs. Caucasian, 1,992 | 1.00 (1.00; 1.00)
N = 18,224 | Fecal incontinence | Non-Caucasian vs. Caucasian, 1,993 | 1.30 (1.00; 1.70)
Nelson 2005, ^407^ | Combined urinary and fecal | Non Whites vs. Whites | 2.00 (1.20; 3.40)*
N = 8,170 | Fecal incontinence | Non Whites vs. Whites | 2.10 (1.30; 3.40*

Bold- multivariate odds ratios

* - Significant incontinence odds ratio 95% CI

Table F35 Prevalence of FI in community dwelling adults by diet, body mass index, and the presence of diabetes

Author | Population subgroup | Symptoms | Prevalence, %
Alcohol
Melville, 2005 ^338^ | Moderate alcohol, women | Fecal incontinence | 0.84
N = 3,444
BMI in women
Richter, 2005 ^406^ | BMI>40, undergoing laparoscopic weight loss surgery | Anal incontinence | 32.00
N = 180
Ng, 2002 ^408^ | Body mass index >20 | Anal incontinence | 12.81
N = 320
Richter, 2005 ^406^ | BMI>40, undergoing laparoscopic weight loss surgery | Flatus | 14.44
N = 180 | BMI>40, undergoing laparoscopic weight loss surgery | Flatus and liquid feces | 7.79
| BMI>40, undergoing laparoscopic weight loss surgery | Liquid feces | 6.68
| BMI>40, undergoing laparoscopic weight loss surgery | Solid or liquid feces | 2.79
Diabetes
Meschia, 2002 ^409^ | Women | Anal incontinence | 0.91
N = 881
Melville, 2005 ^338^ | Women | Fecal incontinence | 1.13
N = 3,444
Jackson, 1997 ^303^ | Women | Fecal incontinence | 21.4
N = 14
Bytzer, 2001 ^351^ | Men and women | Solid feces | 2.60
N = 423 | | Solid or liquid feces | 12.80

Table F36 Association between severity of FI and BMI

Author | Definition of Incontinence | Risk Factors in Population Groups | Relative Risk (95%CI))
Sample
Guise, 2007 ^410^ | Persistent Incontinence of stool | BMI before the birth ≥30 vs. <30 | 1.70 (1.37; 2.11)*
N = 8,774
Hojberg, 2000 ^215^ | Isolated flatus incontinence at least once a week | Pre-pregnancy BMI < 20 vs. 20–30 | 0.90 (0.70; 1.20)
N = 7,557 | Isolated flatus incontinence at least once a week | Pre-pregnancy BMI >35 vs. 30–35 | 0.90 (0.30; 2.90)
Bliss, 2004 ^308^ | Soils underwear or floor | Overweight men and women older than 75 years | 1.40 (1.00; 2.00)
N = 1,352

Bold = multivariate odds ratios

* Significant difference

Table F37 Association between physical activity and FI

Author | Fecal Incontinence | Physical Activity in Population Groups | Odds Ratio (95%CI
Sample
Ostbye, 2004 ^28^ | Prevalence of fecal incontinence | Frequent exercise in women | 0.75 (0.53; 1.05)
N = 8,949 | Incidence of fecal incontinence | Frequent exercise in women | 0.9 (0.69; 1.16))
| Prevalence of fecal incontinence | Frequent exercise in men | 0.67 (0.4; 1.14)
| Incidence of fecal incontinence | Frequent exercise in men | 1.05 (0.7; 1.57)
Bradley, 2005 ^64^ | Fecal urgency | Exercise ≥ weekly vs.< weekly | 0.3 (0.2; 0.8)*
N = 297

Bold = multivariate odds ratios

* Significant difference

Table F38 Prevalence of FI in patients with cancer

Author | Age | Definition of Fecal Incontinence | Risk Factor | Prevalence, %
Kienle, 2007 ^411^ | 65 | Anal incontinence, Grade 1 | Deep or standard anterior resection for rectal cancer | 2
N = 100 | | Anal incontinence, Grade 2 | Deep or standard anterior resection for rectal cancer | 2
Welsh, 2003 ^412^ | 76 | Anal incontinence | Survivors of anterior resection of the rectum | 53
N = 124
Tanum, 1991 ^413^ | 35–91 | Anal incontinence | Chemotherapy and radiation therapy for carcinoma of the anal canal | 1.9
N = 106
Norderval, 2004 ^414^ | | Anal incontinence | Proctocolectomy | 1.15
N = 205 | | | Proctocolectomy with J-pouch anastomosis | 25
| | | Proctocolectomy with W-pouch anastomosis | 7
Kienle, 2006 ^411^ | 65 | Pad use, always | Deep or standard anterior resection for rectal cancer | 42
N = 100 | | Pad use, daytime | Deep or standard anterior resection for rectal cancer | 6
| | Pad use, nighttime | Deep or standard anterior resection for rectal cancer | 4
| | Pad use, occasionally | Deep or standard anterior resection for rectal cancer | 8

Table F39 Prevalence of FI in community dwelling adults after stroke

Author | Gender | Condition | Prevalence, %
Sample
Combined urinary and fecal incontinence
Brittain, 2006 ^348^ | Women and Men | Stroke survivors | 4.3
N = 1,483
Fecal Incontinence
Brittain, 2006 ^348^ | Women and Men | Stroke survivors | 7.4
N = 1,483
Otegbayo, 2006 ^239^ | Women | Acute stroke | 3.4
N = 54 | Men | Acute stroke | 8.0
Harari, 2003 ^415^ | Women | 6 months after stroke | 5.3
N = 846 | Women and Men | 1 year after stroke | 10.9
| Women and Men | 3 months after stroke, <65 years old | 1.7
| Women and Men | 3 months after stroke | 10.8
| Women and Men | 3 years after stroke | 15.0
| Women and Men | 3 months after stroke, 65–79 year old | 5.0
| Women and Men | 3 months after stroke, >80 years old | 4.1
| Women and Men | 7 to 10 days after stroke | 29.7
| Women and Men | Nonwhite 3 months after stroke | 2.2
| Women and Men | White 3 months after stroke | 8.4
Nakayama, 1997 ^416^ | Women and Men | 6 months after stroke | 5.0
N = 935 | Women and Men | acute stroke | 34.0
| Women and Men | At Discharge after stroke | 12.0
Otegbayo, 2006 ^239^ | Women and Men | Ischemic acute stroke | 9.7
N = 54 | Women and Men | Left acute stroke | 3.6
| Women and Men | Right acute stroke | 7.7
| Women and Men | Acute stroke | 5.6
Brittain, 2006, ^348^ | Women and Men | Stroke survivors | 0.8
N = 1,483 | Women and Men | Furnishing or bedding in stroke survivors | 27.0
| Women and Men | Stroke survivors | 7.0
| Women and Men | Soiling underwear in stroke survivors | 66.0
Major fecal incontinence
Brittain, 2006, ^348^ | Women and Men | Stroke survivors | 5.0
N = 1,483
Partial fecal incontinence
Nakayama, 1997 ^416^ | Women and Men | 6months after stroke | 4.0
N = 935 | Women and Men | Acute stroke | 6.0
| Women and Men | At discharge after stroke | 6.0

Table F40 Prevalence of fecal incontinence in patients with neurological disease

Author | Neurological Disease | Fecal Incontinence | Prevalence, %
Sakakibara, 2001 ^282^ | Parkinson's disease in men | Fecal incontinence | 10
N = 323 men and 183 women | Parkinson's disease in women | Fecal incontinence | 5
Menter, 1997 ^266^ | Spinal cord injury | Fecal incontinence | 6.3
N = 227 | Tetraplegia | Fecal incontinence | 13.8
| Paraplegia | Fecal incontinence | 3.7
| Incomplete injuries (ASIA Impairment D) | Fecal incontinence | 2.1
Hinds, 1990 ^213^ | Multiple sclerosis | Fecal incontinence | 51.0
N = 280
Ho, 2005 ^417^ | Multiple sclerosis | Fecal incontinence | 20.7
N = 434
Hinds, 1990 ^213^ | Multiple sclerosis | Fecal incontinence, >1/week | 25.0
N = 280
Ho, 2005 ^417^ | Multiple sclerosis | Major soiling of underclothes | 7.6
N = 434 | | Minimal soiling of underclothes | 11.3
| | Passive soiling, always | 2.5
| | Passive soiling, never | 6.7
| | Passive soiling, sometimes | 11.3
| | Soiling weekly | 4.8
| | Soiling daily | 2.3
| | Soiling less often | 9.2
| | Soiling monthly | 3.2
| | Soiling of furniture | 0.7
| | Soiling of outer clothes | 0.9
| | Wear pad | 7.1
| | Active soiling, always | 1.4
| | Active soiling, never | 4.4
| | Active soiling, sometimes | 15.0
Hinds, 1990 ^213^ | Multiple sclerosis | Bowel dysfunction (constipation and/or fecal incontinence) | 68.0
N = 280 | Multiple sclerosis | Constipation | 43.0
Ho, 2005 ^417^ | Multiple sclerosis | Consistency of soiling: mainly formed | 5.1
N = 434 | | Consistency of soiling: mainly watery | 9.0

Table F41 Association between FI and pressure ulcers in residents of nursing homes

Author | Definition of Incontinence | Relative Risk (95%CI)
Sample
Nelson, 2005 ^407^ | Combined urinary and anal incontinence | 1.00 (1.00; 1.00)
N = 8,170
Nelson, 1998 ^306^ | Fecal incontinence in 1992 | 2.60 (2.20; 3.00)
N = 18,224 | Fecal incontinence 1993 | 2.30 (2.00; 2.60)

Bold = multivariate odds ratios

Table F42 Association between FI and gastrointestinal conditions in residents of nursing homes

Author | Risk Factors | Odds Ratio 95%CI
Sample
Combined UI and FI
Nelson, 2005 ^407^ | Constipation | 1.00 (1.00; 1.00)
N = 8,170 | Diarrhea | 1.00 (1.00; 1.00)
| Fecal impaction | 1.00 (1.00; 1.00)
FI
Nelson, 2005 ^407^ | Constipation | 1.00 (1.00; 1.00)
N = 8,170 | Diarrhea | 1.00 (1.00; 1.00)
| Fecal impaction | 1.00 (1.00; 1.00)
Nelson, 1998 ^306^ | Constipation, 1992 | 1.40 (1.30; 1.60)*
N = 18,224 | Diarrhea, 1992 | 3.30 (2.70; 4.20)*
| Fecal impaction, 1992 | 1.50 (1.10; 2.10)*
| Constipation, 1993 | 1.30 (1.20; 1.40)*
| Diarrhea, 1993 | 2.40 (1.90; 3.10)*
| Fecal impaction, 1993 | 2.10 (1.30; 3.30)*

Bold = multivariate odds ratios

* Significant difference

Table F43 Association between type and severity of FI and gastrointestinal conditions

Author | Age | Risk Factors in Population Groups | Fecal Incontinence | Odds Ratio 95%CI
Sample
Bliss, 2004 ^308^ | Mean age of 75+-6 | Bowel resection | Severity, fecal incontinence ≥1 times/day | 3.2 (1.5; 6.6)*
N = 1,352 | | Defecation urgency always | Severity, soils underwear or floor | 11.9 (4.9; 28.8)*
| | Defecation urgency most of the time | Severity, soils underwear or floor | 5 (3; 8.6)*
| | Defecation urgency some of the time | Severity, soils underwear or floor | 2.8 (2; 4.1)*
| | Loose or liquid stool consistency | Severity, having fecal incontinence ≥1 times/day | 2.4 (1.3; 4.3)*
| | Loose or liquid stool consistency | Severity, soils underwear or floor | 3 (1.5; 5.8)*
| | Urgency always | Severity, having fecal incontinence ≥1 times/day | 11.4 (5.1; 25.5)*
| | Urgency most of the time | Severity, fecal incontinence ≥1 times/day | 4.7 (2.8; 7.6)*
| | Urgency some of the time | Severity, fecal incontinence ≥1 times/day | 3 (2.1; 4.3)*
| | Hemorrhoids | Severity, fecal incontinence ≥1 times/day | 1.6 (1.1; 2.3)*
| | Hemorrhoids | Severity, soils underwear or floor | 1.5 (1.1; 2.2)*
| | Defecation urgency some of the time | Type, liquid feces | 2.1 (1.4; 3.2)*
| | Defecation urgency always | Type, solid feces | 20.3 (2.9; 11.3)*
| | Defecation urgency most of the time | Type, solid feces | 4.3 (0.9; 17.4)
| | Loose or liquid stool consistency | Type, liquid feces | 2.8 (1.3; 6.1)*
| | Had surgery for hemorrhoids | Type, liquid feces | 2.5 (1.4; 4.3)*
Johanson, 1997 ^418^ | 31–103 | Frequent diarrhea | Type, liquid feces | 2.5 (1.5; 4.2)*
N = 388 | | Straining | Type, solid feces | 0.7 (0.3; 0.9)
| | Straining | Type, liquid feces | 0.7 (0.5; 0.9)
| | Watery stool | Type, liquid feces | 2.5 (1.5; 4)*
Uustal Fornell, 2004 ^208^ | >40 | Hemorrhoid operation in women | Flatus | 1.60 (0.50; 4.80)
N = 885 | | | Type, liquid feces | 2.60 (1.00; 6.10)
| | | Type, solid feces | 1.50 (0.00; 9.30)

Bold = multivariate odds ratios

* Significant difference

Table F44 Prevalence of FI after gastro-intestinal surgery

Author | Gastro-Intestinal Surgery | Definition of FI | Prevalence of FI
Reissman, 1996 ^419^ | Double stapled ileoanal reservoir ulcerative colitis or familial adenomatous polyposis | Fecal incontinence during the day | 7%
N = 14 >60 years | Double stapled ileoanal reservoir ulcerative colitis or familial adenomatous polyposis | Fecal incontinence during the day | 5%
N = 126 <60 years
Lohmuller, 1990 ^420^ | Inflammatory bowel disease after ileal pouch-anal anastomosis and Pouchitis | Frequent fecal incontinence | 11%
N = 734 | Inflammatory bowel disease after ileal pouch-anal anastomosis | Frequent fecal incontinence | 8%
| Inflammatory bowel disease after ileal pouch-anal anastomosis and Pouchitis | Occasional fecal incontinence | 43%
| Inflammatory bowel disease after ileal pouch-anal anastomosis | Occasional fecal incontinence | 35%
Gonzalez-Argente, 2001 ^421^ | Surgery for rectal prolapse in women | Fecal incontinence | 97%
N = 32

Table F45 Association between FI and surgical procedures

Author | Age | Risk Factors in Population Groups | Odds Ratio (95% CI)
Sample
Anal incontinence
Chen, 2003 ^284^ | ≥20 | Gynecological surgery | 1.8 (1.1; 2.9)*
N = 1,253
100% female
Ng, 2002 ^408^ | | Prior pelvic surgery | 1.64 (0.79; 3.42)
N = 320
100% female
Fecal incontinence
Bharucha, 2006 ^422^ | ≥20 | Anorectal surgery | 1.2 (0.7; 2.1)
N = 2,800
100% female
Kalantar, 2002 ^339^ | > 18 | Perianal surgery | 4.62 (2.05; 10.4)*
N = 642
55% female
Severity of incontinence
Bliss, 2004 ^308^ | mean age of 75+-6 | Soils underwear or floor after bowel resection | 2.2 (1.1; 4.5)*
N = 1,352
60% female
Hojberg, 2000 ^215^ | ≥15 | Isolated flatus incontinence ≥1/week after previous lower abdominal or urological surgery | 1.5 (1.1; 2.1)*
N = 1726
Flatus incontinence
Uustal Fornell, 2004 ^208^ | >40 | Groin hernia needing surgery | 1.50 (0.40; 5.40)
N = 885 | | Hiatus hernia | 1.10 (0.30; 3.60)
100% female | | Varicose veins needing surgery | 1.00 (0.60; 1.50)
Liquid feces
Uustal Fornell, 2004 ^208^ | >40 | Groin hernia needing surgery | 3.00 (1.10; 8.30)*
N = 885 | | Hiatus hernia | 4.30 (1.60; 11.30)*
100% female | | Varicose veins needing surgery | 1.00 (0.60; 1.70)
Solid feces
Johanson, 1997 ^418^ | 31–103 | Rectal surgery | 0.4 (0.2; 0.9)
N = 338
76% female
Uustal Fornell, 2004 ^208^ | >40 | Groin hernia needing surgery | 4.00 (0.00; 16.30)
N = 885 | | Hiatus hernia | 5.90 (1.80; 19.80)*
100% female | | Varicose veins needing surgery | 1.90 (0.80; 4.10)

Bold = multivariate odds ratios

* Significant difference

Table F46 Association between fecal incontinence and drug administration

Author | Age | Drug | Odds Ratio (95%CI)
Sample
Combined urinary and fecal incontinence
Endo, 2002 ^304^ | | Cathartic/laxative use | 1.902 (1.078; 3.355)*
N = 605 | | Diuretic use | 2.226 (1.264; 3.921)*
Fecal incontinence
Quander ^232^ | >65 | Antacids | 1.4 (0.90; 2.00)
N = 6,099 | | Anticonvulsant | 1.90 (1.90; 3.20)*
| | Antidepressants | 1.90 (1.20; 3.00)*
| | Anti Parkinson | 4.30 (2.50; 5.30)*
| | Antipsychotic | 3.90 (2.50; 6.20)*
| | Beta blocker | 0.8 (0.60; 1.10)
| | Benzodiazepine | 0.8 (0.50; 1.50)
| | Calcium channel blocker | 0.7 (0.60; 0.90)
| | Diuretic | 1.1 (0.90; 1.40)
| | Estrogen | 0.7 (0.40; 1.40)
| | Fiber | 1.6 (0.90; 2.90)
| | Hypnotics | 3.10 (1.80; 4.80)*
| | Iron | 0.8 (0.20; 2.50)
| | Narcotics | 1.70 (1.20; 2.50)*
Bliss, 2004 ^308^ | mean age of 75+-6 | Fecal incontinence ≥1 times/day after daily administration of stool softener for constipation | 2.1 (1.1; 3.7)*
N = 1,352
Richter, 2005 ^406^ | 16–55 | Anal incontinence: Diuretics in morbid obese before laparoscopic weight loss surgery | 0.78 (0.39; 1.58)
N = 180
Hormone therapy in women
Richter, 2005 ^406^ | 16–55 | Anal incontinence: hormone replacement therapy in morbid obese before laparoscopic weight loss surgery | 0.87 (0.40; 1.92)
N = 180
Bharucha, 2006 ^422^ | ≥20 | Fecal incontinence: hormone therapy - current | 1 (0.8; 1.6)
N = 2,800 | | Fecal incontinence: contraceptive use | 1.3 (0.98; 1.8)

Bold = multivariate odds ratios

* Significant difference

Table F47 Prevalence of FI in men with prostate diseases

Author | Risk Factor | Definition of Fecal Incontinence | Prevalence, %
Sample
Korman, 2004 ^288^ | Perineal prostatectomy | Fecal incontinence | 5.4
N = 201 | Retropubic prostatectomy | Fecal incontinence | 6.4
O'Connell, 2007 ^423^ | Prostate surgery more than a year ago | Fecal incontinence >1/day | 3.4
N = 212 | Prostate surgery more than a year ago | Fecal incontinence >1/week | 3.9
| Prostate surgery more than a year ago | Fecal incontinence 1/day | 8.2
| Prostate surgery more than a year ago | Loosing control of stools as a big problem | 1.1
Adolfsson, 1998 ^252^ | Prostate cancer | Solid or liquid feces | 8.0
N = 661 | Prostate cancer | Urgency | 22.0
| Prostate cancer | Constipation | 20.0

Table F48 Association between FI and abortion in women

Author | Definition of Fecal Incontinence | Abortion | Odds Ratio (95%CI)
Sample
Hojberg, 2000 ^215^ | Severity, isolated flatus incontinence ≥1/week | Previous abortions <12 weeks of gestation | 1 (0.8; 1.3)
| Severity, isolated flatus incontinence ≥1/week | Previous abortions >12 weeks of gestation | 0.7 (0.3; 1.6)

Bold = multivariate odds ratios

Table F49 Association between FI and menopause

Author | Age | Definition of Fecal Incontinence | Odds Ratio (95%CI)
Sample
Ng, 2002 ^408^ | | Anal incontinence | 0.91(0.52; 1.60)
N = 320
Chen, 2003 ^284^ | ≥20 | Anal incontinence | 0.6 (0.3; 1.1)
N = 1,253
Abramov, 2005 ^424^ | 26–86 | Fecal incontinence | 2.1 (1.15; 3.8)*
N = 542 | | Flatus incontinence | 2.11 (1.43; 3.13)*

Bold = multivariate odds ratios

* Significant difference

Table F50 Association between FI and UI in residents of nursing homes

Author | Year of Observation | Age | Odds Ratio (95%CI)
Nelson, 1998 ^306^ | 1992 | 84 | 12.60 (11.50; 13.70)*
N = 18,224 | 1993 | 84 | 11.30 (10.30; 12.40)*

Bold = multivariate odds ratios

* Significant difference

Table F51 Prevalence of FI in patients with prolapse and in women with UI

Author | Risk Factor | Prevalence, %
Sample
Anal incontinence
Weber, 1998 ^425^ | Vaginal prolapse | 16.10
N = 143 | Vaginal prolapse - Stage 0 | 8.70
| Vaginal prolapse - Stage 1 | 39.10
| Vaginal prolapse - Stage 2 | 30.40
| Vaginal prolapse - Stage 3 | 21.80
Rose, 2002 ^223^ | Rectal prolapse in men and women | 30.70
N = 150
Fecal incontinence
Soligo, 2006 ^426^ | Urogynecologic symptoms | 20.00
N = 786
Meschia, 2002 ^409^ | Genital prolapse >2 grade | 8.17
N = 881
Ng, 2002 ^408^ | Genuine stress incontinence | 3.75
N = 320 | Mixed urinary incontinence | 2.8
| Overactive bladder | 6.25
| Prior pelvic surgery for prolapse | 6.88
Meschia, 2002 ^409^ | Prolapse repair | 2.16
N = 881
Leroi, 1999 ^427^ | Stress urinary incontinence | 28.00
N = 409
Meschia, 2002 ^409^ | Urinary incontinence and/or genital prolapse | 20.00
N = 881
Ng, 2002 ^408^ | Urinary symptoms | 15.90
N = 320 | Uterovaginal prolapse | 12.19
Parmentier, 2004 ^428^ | Pelvic organ prolapse | 26.10
N = 291
Combined urinary and fecal incontinence
Soligo, 2003 ^429^ 2 | Urogynecologic symptoms | 20.24
N = 504
Meschia, 2002 ^409^ | Urinary incontinence and/or genital prolapse | 13.90
N = 881
Jelovsek, 2005 ^430^ | Urinary incontinence or pelvic organ prolapse | 22.00
N = 152
Fecal incontinence
Melville, 2005 ^338^ | Urinary incontinence | 4.82
N = 3,444
Jelovsek, 2005 ^430^ | Urinary incontinence or pelvic organ prolapse | 19.00
N = 302
Jackson, 1997 ^303^ | Anterior colporrhaphy (n=27) | 22.22
| Posterior colporrhaphy (n=22) | 22.73
| Prolapse >1st degree (n=139) | 24.46
| Prolapse >2nd degree (n=71) | 26.76
| Prolapse >3rd degree (n=46) | 26.09
| Prolapse repair (n=46) | 26.67
| Urinary incontinence or pelvic organ prolapse (n=247) | 17.00
Flatus incontinence
Leroi, 1999 ^427^ | Stress urinary incontinence | 18.30
N = 409
Ng, 2002 ^408^ | Urinary symptoms | 12.30
N = 320
Liquid feces incontinence
Leroi, 1999 ^427^ | Stress urinary incontinence | 9.50
N = 409
Passive fecal incontinence
Soligo, 2003 ^429^ | Urogynecologic symptoms | 8.73
N = 504
Soiling
Jelovsek, 2005 ^430^ | Urinary incontinence or pelvic organ prolapse | 12.00
N = 302
Solid and liquid feces
Ng, 2002 ^408^ | Urinary symptoms | 3.60
N = 320
Leroi, 1999 ^427^ | Stress urinary incontinence | 3.60
N = 409
Solid feces
Leroi, 1999 ^427^ | Stress urinary incontinence | 1.00
N = 409
Jelovsek, 2005 ^430^ | Urinary incontinence or pelvic organ prolapse | 7.00
N = 302
Solid or liquid feces
Khullar, 1998 ^276^ | Mild stress urinary incontinence | 14.81
N = 465 | Moderate stress urinary incontinence | 24.19
| Severe stress urinary incontinence | 11.70
Urge fecal incontinence
Soligo, 2003 ^429^ | Urogynecologic symptoms | 9.33
N = 504
Soligo, 2006 ^426^ | Urogynecologic symptoms | 11.20
N = 786

Table F52 Association between FI and prolapse in women

Author | Age | Risk Factor | Odds Ratio (95%CI)
Sample
Anal incontinence
Meschia, 2002 ^409^ | 58.6 | Douglas >grade 2 | 1.50 (0.60; 3.50)
N = 881 | | Perineum >grade 2 | 1.40 (0.70; 2.80)
| | Prolapse of Bladder >2 grade | 0.90 (0.60; 1.20)
| | Prolapse of Cervix/cuff >2 grade | 0.80 (0.50; 1.30)
| | Prolapse of Douglas >2 grade | 2.20 (1.10; 4.40)*
| | Prolapse of Perineum >2 grade | 1.80 (1.00; 3.30)
| | Prolapse of Rectum >2 grade | 2.00 (1.20; 3.10)
| | Prolapse of Urethra >2 grade | 0.90 (0.60; 1.40)
| | Rectum >grade 2 | 1.90 (1.10; 3.30)*
Ng, 2002 ^408^ | | Utero vaginal prolapse | 5.02 (2.19; 11.54)*
N = 320
Chen, 2003 ^284^ | ≥20 | Utero vaginal prolapse | 3.2 (1.1; 8.9)*
N = 1,253
Flatus incontinence
Uustal Fornell, 2004 ^208^ | >40 | Bulge | 2.80 (1.20; 6.40)
N = 885 | | Digitation by defecation | 2.10 (1.30; 3.60)*
| | Pelvic heaviness | 2.30 (1.50; 3.60)*
Liquid incontinence
Uustal Fornell, 2004 ^208^ | >40 | Bulge | 1.40 (0.50; 3.50)
N = 885 | | Digitation by defecation | 1.80 (1.10; 3.00)*
| | Pelvic heaviness | 4.20 (2.70; 6.40)
Solid incontinence
Uustal Fornell, 2004 ^208^ | >40 | Bulge | 1.80 (0.00; 7.20)
N = 885 | | Digitation by defecation | 1.40 (0.60; 3.70)
| | Pelvic heaviness | 3.30 (1.60; 7.00)

Bold = multivariate odds ratios

* Significant difference

Table F53 Association between severity of FI and UI

Author | Fecal Incontinence | Urinary Symptoms | Odds Ratio (95%CI)
Sample
Kjolhede, 2005 ^431^ | Urgency (n = 508) | Burch colposuspension for urinary incontinence vs. healthy controls 14 years after surgery | 1.18 (0.60; 2.30)
N = 508 | Severity, flatus, weekly or more often (n = 495) | Burch colposuspension | 1.98 (1.17; 3.37)*
| Severity, liquid, weekly or more often (n = 495) | Burch colposuspension | 3.67 (1.43; 9.42)*
| Severity, solid, weekly or more often (n = 495) | Burch colposuspension | 2.96 (0.42; 20.9)
| Severity, soils underclothes (soiling from the bowel) (n = 495) | Burch colposuspension | 2.02 (0.93; 4.42)
| Soiling underclothes | Burch colposuspension for urinary incontinence vs. healthy controls 14 years after surgery | 1.44 (0.75; 2.77)
| Wear pad during a day | Burch colposuspension for urinary incontinence vs. healthy controls 14 years after surgery | 3.22 (1.30; 7.95)*
| Adverse affect on general well-being | Burch colposuspension for urinary incontinence vs. healthy controls 14 years after surgery | 2.15 (1.30; 3.56)*
| Adverse effect on social activities/social life | Burch colposuspension for urinary incontinence vs. healthy controls 14 years after surgery | 1.39 (0.73; 2.65)
| Avoiding activities because of incontinence | Burch colposuspension for urinary incontinence vs. healthy controls 14 years after surgery | 2.02 (0.88; 4.64)
Nichols, 2005 ^432^ | Bothersome anal incontinence | Stage II pelvic organ prolapse and/or urinary incontinence vs. stage 0 or I pelvic organ prolapse and no urinary incontinence | 5.40 (2.80; 10.60)*
N = 190 | | Stage II pelvic organ prolapse and/or urinary incontinence vs. stage 0 or I pelvic organ prolapse and no urinary incontinence | 4.90 (2.10; 11.80)*
Bliss, 2004 ^308^ | Severity, having fecal incontinence≥1 time/day | Urinary incontinence in men and women | 2.5 (1.8; 3.4)*
N = 1,352
Kjolhed, 2005 ^431^ | Frequent soiling underclothes | Burch colposuspension for urinary incontinence vs. healthy controls 14 years after surgery | 2.02 (0.93; 4.42)
N = 508

Bold = multivariate odds ratios

* Significant difference

Table F54 Prevalence of FI related to pregnancy and birth

Author | Risk Factors | Prevalence, %
Sample
Anal incontinence
Groutz, 1999 ^433^ | No posterolateral episiotomy | 2.30
N = 300 | 1 year after delivery | 4.67
| 3 months after delivery | 7.00
Bugg, 2005 ^434^ | 10 months postpartum | 9.10
N = 275
Sze, 2005 ^435^ | Complete 3rd-degree perineal laceration, n = 65 | 16.92
| Complete 3rd-degree tear as a nullipara, n = 234 | 14.53
| Complete 3rd-degree tear as a nullipara and > 2 deliveries, n = 40 | 30.00
| Complete 3rd-degree tear as a nullipara and 1 delivery, n = 67 | 16.42
| Complete 3rd-degree tear as a nullipara and no vaginal delivery, n = 65 | 16.92
Sze, 2005 ^436^ | 4th-degree sphincter tear as a nullipara, n = 148 | 30.20
| 4th-degree sphincter tear as a nullipara, n = 50 | 40.00
| 1- Delivery after 4th-degree sphincter tear as a nullipara, n = 60 | 23.33
| 2- Delivery after 4th-degree sphincter tear as a nullipara, n = 36 | 27.78
| Sphincter tears and ≥ 2 additional vaginal deliveries, n = 37 | 27.03
Hojberg, 2000 ^215^ | Pregnant women with one previous delivery | 8.60
N = 1,726
Parmentier, 2004 ^428^ | Forceps delivery | 5.16
N = 291
Meschia, 2002 ^409^ | Forceps delivery | 2.38
N = 881 | Episiotomy | 12.94
| Infant weighing >3800g | 8.85
| Vacuum | 0.57
Ng, 2002 ^408^ | Vaginal delivery history | 13.44
N = 320
Any fecal incontinence
Chiarelli, 2003 ^286^ | Multiparous, n = 270 | 8.50
| Primiparous, n = 298 | 5.40
Bothersome fecal incontinence
Nygaard, 1997 ^437^ | 30 years postpartum after Cesarean, n = 33 | 15.20
| 30 years postpartum after Episiotomy, n = 89 | 25.80
| 30 years postpartum with anal disruption, n = 29 | 27.60
Combined urinary and fecal incontinence
Bugg, 2005 ^434^ | 10 months postpartum | 5.50
N = 275
Groutz, 1999 ^433^ | 2 year after delivery | 1.67
N = 300
Fecal incontinence
Jackson, 1997 ^303^ | Episiotomy, n = 218 | 12.84
| Forceps, n = 192 | 6.25
Melville, 2005 ^338^ | Nonoperative vaginal delivery | 2.90
N = 3,444 | Nulliparous | 1.05
| Cesarean sections only | 0.29
McKinnie, 2005 ^438^ | Pregnant women | 12.75
N = 1,004
Goldberg, 2003 ^285^ | Previous multiple pregnancy | 10.00
N = 733
Walsh, 1996 ^439^ | 3rd-degree tear primary repair | 7.00
N = 81
Fecal urgency
Mazouni, 2005 ^228^ | 12 months after instrumental delivery | 8.20
N = 159
Flatus incontinence
Chiarelli, 2003 ^286^ | 12 months after instrumental delivery and/or a high birth weight infant | 24.40
N = 568
Groutz, 1999 ^433^ | 3 months after delivery | 6.30
N = 300
Nygaard, 1997 ^437^ | 30 years postpartum after Cesarean, n = 33 | 15.20
| 30 years postpartum after Cesarean, n = 33 | 57.60
| 30 years postpartum after Episiotomy, n = 89 | 30.30
| 30 years postpartum after Episiotomy, n = 89 | 69.70
| 30 years postpartum with anal disruption, n = 29 | 58.60
| 30 years postpartum with anal disruption, n = 29 | 75.90
Chiarelli, 2003 ^286^ | Multiparous | 24.80
N = 270
Hojberg, 2000 ^215^ | Pregnant women with 1 previous delivery | 4.20
N = 1,726
Goldberg, 2003 ^285^ | Previous multiple pregnancy | 25.20
N = 733
Chiarelli, 2003 ^286^ | Primiparous | 24.10
N = 298
Walsh, 1996 ^439^ | 3rd-degree tear primary repair | 12.00
N = 81
Mazouni, 2006 ^228^ | 13 months after instrumental delivery | 7.50
N = 159
Liquid feces incontinence
Chiarelli, 2003 ^286^ | 12 months after instrumental delivery and/or a high birth weight infant | 4.90
N = 568
Hojberg, 2000 ^215^ | Pregnant women with 1 previous delivery | 2.30
N = 1,726
Chiarelli, 2003 ^286^ | Multiparous, n = 270 | 5.90
| Primiparous, n = 298 | 4.00
Soiling
Chiarelli, 2003 ^286^ | Multiparous | 14.80
N = 270
Goldberg, 2003 ^285^ | Previous multiple pregnancy | 10.00
N = 733
Chiarelli, 2003 ^286^ | Primiparous | 7.40
N = 298
Solid feces incontinence
Bugg, 2005 ^434^ | 10 months postpartum | 3.00
N = 275
Chiarelli, 2003 ^286^ | 12 months after instrumental delivery and/or a high birth weight infant | 2.60
N = 568
Groutz, 1999 ^433^ | 3 months after delivery | 0.70
N = 300
Hojberg, 2000 ^215^ | Pregnant women with 1 previous delivery | 0.60
N = 1,726
Chiarelli, 2003 ^286^ | Multiparous, n = 270 | 3.00
| Primiparous, n = 298 | 2.30
Urgency
Chiarelli, 2003 ^286^ | Multiparous, n = 270 | 18.90
| Primiparous, n = 298 | 11.00
| 12 months after instrumental delivery and/or a high birth weight infant, n = 568 | 14.80
Urgency and incontinence
Sangalli, 2000 ^234^ | 13 years obstetrical anal sphincter tear | 22.48
N = 129

Table F55 Incidence and severity of FI related to pregnancy and birth

Author | Risk Factors | Fecal Incontinence | Prevalence %
Sample
Norderval, 2004 ^414^ | 25 months after primary repair of obstetric sphincter tears | Incidence of anal incontinence, total | 45.30
N = 150 | | Incidence of Flatus | 24.00
| | Incidence of Flatus <1/week | 7.30
| | Incidence of Flatus >1/week | 12.00
| | Incidence of Flatus Daily | 4.70
| | Incidence of Incontinence to liquid stool | 13.30
| | Incidence of Incontinence to liquid stool <1/week | 12.70
| | Incidence of Incontinence to liquid stool >1/week | 0.70
| | Incidence of Incontinence of solid feces | 8.00
| | Incidence of Incontinence of solid feces <1/week | 4.70
| | Incidence of Incontinence of solid feces Daily | 0.70
Impact on life
Sze, 2005 ^436^ | 1- Delivery after 4th-degree sphincter tear as a nullipara | Little effect on daily activities, n = 60 | 3.33
| 2- Delivery after 4th-degree sphincter tear as a nullipara | Little effect on daily activities, n =36 | 5.56
| 4th-degree sphincter tear as a nullipara | Little effect on daily activities, n =50 | 8.00
| 1- Delivery after 4th-degree sphincter tear as a nullipara | No effect on daily activities, n =60 | 20.00
| 2- Delivery after 4th-degree sphincter tear as a nullipara | No effect on daily activities, n =36 | 11.11
| 4th-degree sphincter tear as a nullipara | No effect on daily activities, n =50 | 32.00
Macarthur, 2005 ^404^ | 3 months and 6 years postpartum | Persistent fecal incontinence | 3.60
N = 4,214
Sze, 2005 ^435^ | Complete 3rd-degree perineal laceration | Severe anal incontinence, n =65 | 3.08
15970289 | Complete 3rd-degree tear as a nullipara | Severe anal incontinence, n =234 | 2.14
| Complete 3rd-degree tear as a nullipara and > 2 deliveries | Severe anal incontinence, n =40 | 5.00
| Complete 3rd-degree tear as a nullipara and 1 delivery | Severe anal incontinence, n =67 | 1.49
| Complete 3rd-degree tear as a nullipara and no vaginal delivery | Severe anal incontinence, n =65 | 3.08
| Sphincter tears and ≥ 2 additional vaginal deliveries | Severe fecal incontinence, n =37 | 5.41
Sze, 2005 ^436^ | 1- Delivery after 4th-degree sphincter tear as a nullipara | Severe effect on daily activities, n =60 | 0.00
| 2- Delivery after 4th-degree sphincter tear as a nullipara | Severe effect on daily activities, n =36 | 11.11
| 4th-degree sphincter tear as a nullipara | Severe effect on daily activities, n =50 | 0.00
| 1- Delivery after 4th-degree sphincter tear as a nullipara | Severe incontinence, n =60 | 0.00
| 2- Delivery after 4th-degree sphincter tear as a nullipara | Severe incontinence, n =36 | 11.11
| 4th-degree sphincter tear as a nullipara | Severe incontinence, n = 50 | 0.00
Soiling
Chiarelli, 2003 ^286^ | 12 months after instrumental delivery and/or a high birth weight infant | Soiling of the underwear | 10.90
N = 568
Solid feces
Chiarelli, 2003 ^286^ | 12 months after instrumental delivery and/or a high birth weight infant | Solid and liquid feces | 6.90
N = 568
Sangalli, 2000 ^234^ | 13 years obstetrical anal sphincter tear | Solid or liquid feces | 6.98
N = 129
Eason, 2002 ^283^ | 3 months post partum | Solid or liquid feces, once daily | 0.20
N = 949 | | Solid or liquid feces, <once weekly | 2.30
| | Solid or liquid feces, >once daily | 0.10
| | Solid or liquid feces, 1–6 times weekly | 0.40
Sangalli, 2000 ^234^ | 13 years obstetrical anal sphincter tear | Solid or liquid feces, flatus | 11.63
N = 129
Norderval, 2004 ^414^ 2 | 25 months after primary repair of obstetric sphincter tears | Incontinence solid feces >1/week | 2.70
N = 150
Bowel control
Fenner, 2003 ^287^ | 6 months after delivery | N = 831 | 21.70
| 4-degree lacerations | Worse bowel control, n = 165 | 30.80
| 3rd-degree lacerations | Worse bowel control, n= 666 | 3.60

Table F56 Association between fetal characteristics and FI

Author | Fetal Risk Factors | Fecal Incontinence | Odds Ratio (95%CI)
Sample
Chaliha, 1999 ^326^ | Fetal head circumference | Fecal urgency, 3 months postpartum | 1 (0.7; 1.4)
N = 549 | | Flatus incontinence, 3 months postpartum | 0.9 (0.6; 1.2)
Frudinger, 2002 ^440^ | Fetal head circumference | Anal incontinence | 1.11 (0.74; 1.67)
N = 134
Chaliha, 1999 ^326^ | Fetal weight | Fecal urgency, 3 months postpartum | 1 (0.6; 6.8)
N = 549 | | Flatus incontinence, 3 months postpartum | 2.9 (0.8′; 10.2)
Eason, 2002 ^283^ | Fetal weight, <4,000g | Anal incontinence, 3 months postpartum | 1 (1; 1)
N = 252
Casey, 2005 ^367^ | Fetal weight, >4,000g | Anal incontinence, within 7 months of delivery, at or before their 6month contraceptive follow up after delivery | 2.4 (1.3; 4.4)*
N = 3,887
Frudinger ^440^ | Fetal weight, (kg) | Anal incontinence | 1.31 (0.34; 4.99)
N = 134
Guise, 2007 ^410^ | Fetal weight, ≥4,000g | Solid feces incontinence | 0.92 (0.73; 1.15)
N = 8,774
Abramov, 2005 ^424^ | At least 1 Fetal weight, >4,000g | Fecal incontinence | 1.19 (0.56; 2.53)
N = 274 | | Flatus incontinence | 1.02 (0.63; 1.63)
Faltin, 2001 ^328^ | Fetal weight ≤4,000g | Fecal urgency | 1 (1; 1)
N = 1,228 | Fetal weight >4,000g | Fecal urgency | 1.5 (0.7; 3.1)
Mazouni, 2005 ^228^ | Fetal weight (g) | Fecal incontinence, 18 months instrumental delivery | 1.00 (1.00; 1.00)
N = 159
Casey, 2005 ^367^ | Fetal weight t, ≤4,000g | Fecal incontinence, within 7months of delivery, at or before their 6-month contraceptive follow up after delivery | 1 (1; 1)
N = 3,887
van Brummen, 2006 ^441^ | Fetal weight, 3,107g | Fecal incontinence, 1 year after delivery | 0.99 (0.99; 1.01)
N = 487 | Fetal weight, 3,445g | Fecal incontinence, 1 year after delivery | 1.00 (1.00; 1.00)
Guise, 2007 ^410^ | Heaviest fetal weight, ≥4,000g | Solid feces incontinence | 0.85 (0.69; 1.04)
N = 8,774
Eason, 2002 ^283^ | Fetal weight, ≥4,000g | Anal incontinence, 3 months postpartum | 1.2 (0.9; 1.6)
N = 252
Hojberg, 2000 ^215^ | Fetal weight, >4,000g | Flatus incontinence at least once a week, at 16 weeks of gestation in the index-pregnancy | 2.4 (1.1; 5.1)*
Faltin, 2006 ^442^ | Fetal weight, >4,000g vs. <3,000g | >2 symptoms at least once a week or 3 symptoms (flatus, liquid or solid Incontinence, pad use pad; lifestyle alteration), 18 years after rupture of anal sphincter tear during childbirth | 1.21 (0.47; 3.14)
N = 540
Faltin, 2001 ^328^ | Fetal weight, >4,000g vs. <4,000g | Anal incontinence | 0.7 (0.4; 1.4)
N = 1,228
Faltin, 2006 ^442^ | Fetal weight, 3,000–3,499g | >2 symptoms at least once a week or 3 symptoms (flatus, liquid or solid Incontinence, pad use pad; lifestyle alteration), 18 years after rupture of anal sphincter tear during childbirth | 0.74 (0.39; 1.4)
N = 540 | Fetal weight, 3,500–3,999g | >2 symptoms at least once a week or 3 symptoms (flatus, liquid or solid Incontinence, pad use pad; lifestyle alteration), 18 years after rupture of anal sphincter tear during childbirth | 0.86 (0.44; 1.68)

Bold = multivariate odds ratios

* Significant difference

Table F57 Association between FI and mode of delivery

Author | Risk Factor | Definition of Fecal Incontinence | Time From Exposure to Fecal Incontinence | Odds Ratio (95%CI)
Sample
Chaliha, 1999 ^326^ | Augmentation | Fecal incontinence urgency | 3 months postpartum | 0.6 (0.2; 1.6)
N = 549 | Augmentation | Flatus | 3 months postpartum | 0.8 (0.2; 2.8)
| Epidural analgesia | Flatus | 3 months postpartum | 0.9 (0.7; 1.3)
Casey, 2005 ^367^ | Epidural analgesia | Anal incontinence | Within 7 months of delivery, at or before their 6-month contraceptive follow up after delivery | 1.2 (0.7; 1.9)
N = 3,887
Chaliha, 1999 ^326^ | Epidural analgesia | Fecal incontinence urgency | 3 months postpartum | 0.4 (0.1; 1.4)
N = 549
Faltin, 2006 ^442^ | Episiotomy vs. no episiotomy | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | 18 years after rupture of anal sphincter tear during childbirth | 1.04 (0.93; 1.15)
N = 540
Casey, 2005 ^367^ | Episiotomy | Anal incontinence | Within 7 months of delivery, at or before their 6-month contraceptive follow up after delivery | 1 (0.4; 2.3)
N = 3,887
De Leeuw, 2001 ^307^ | Mediolateral episiotomy, primiparity | Fecal incontinence | After anal sphincter damage during delivery | 0.17 (0.05; 0.61)*
N = 250
Eason, 2002 ^283^ | Episiotomy without extension into anal sphincter perineal injury | Anal incontinence | 3 months postpartum | 1.3 (0.9; 1.8)
N = 252
Chiarelli, 2003 ^286^ | Instrumental delivery | Fecal incontinence | At twelve months postpartum | 0.83 (0.31; 2.2)
N = 568 | Marked abdominal striae | Fecal incontinence | At twelve months postpartum | 2.34 (0.91; 6.02)
Casey, 2005 ^367^ | Oxytocin augmentation | Anal incontinence | Within 7 months of delivery, at or before their 6-month contraceptive follow up after delivery | 0.7 (0.3; 1.6)
N = 3,887 | Cesarean delivery | Anal incontinence | | 0.6 (0.2; 2)
Eason, 2002 ^283^ | Cesarean delivery | Anal incontinence | 3 months postpartum | 0.8 (0.6; 1.2)
N = 252
Guise, 2007 ^410^ | Cesarean in this delivery | Solid feces | | 0.94 (0.77; 1.15)
N = 8,774 | Cesarean in this delivery, cesarean labored without push | | | 0.81 (0.53; 1.25)
| Cesarean in this delivery, Cesarean never labored | | | 1 (1; 1)
| Cesarean labored and pushed | | | 0.92 (0.56; 1.52)
| Ever had cesarean | | | 0.92 (0.76; 1.11)
| Pushing time ≥1 hour in this delivery | Severity, incontinence of stool | | 1.22 (1.02; 1.47)*
Chaliha, 1999 ^326^ | Cesarean compared with spontaneous and instrumental vaginal deliveries | Fecal incontinence urgency | 3 months postpartum | 0.8 (0.6; 1.2)
N = 549 | | Flatus | 3 months postpartum | 1.1 (0.6; 2.2)
Melville, 2005 ^338^ | Cesarean deliveries only | Fecal incontinence | | 0.87 (0.42; 1.8)
N = 6,888
MacArthur, 2001 ^405^ | Breech delivery | Fecal incontinence | 3 months postpartum | 1.49 (0.42; 5.24)
N = 7,879
Frudinger, 2002 ^440^ | Caesarean delivery | Anal incontinence | | 0.31 (0.06; 1.62)
N = 134
MacArthur, 2001 ^405^ | Caesarean Section | Fecal incontinence | 3 months postpartum | 0.58 (0.35; 0.97)*
N = 7,879 | | Frequent Fecal incontinence | 3 months postpartum | 0.36 (0.14; 0.98)*
Macarthur, 2005 ^404^ | Caesarean Section | persistent Fecal incontinence | 6 years postpartum among primiparae at index delivery | 0.56 (0.23; 1.37)
N = 4,046 | | Persistent Fecal incontinence | 6 years postpartum | 1.07 (0.64; 1.81)
Faltin, 2006 ^442^ | Cesarean delivery | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | 18 years after rupture of anal sphincter tear during childbirth | 0.61 (0.16; 2.38)
N = 240
Lal, 2001 ^443^ | Cesarean delivery vs. spontaneous vaginal delivery | Anal incontinence | 10 months postpartum | 0.61 (0.25; 1.53)
N = 184 | Cesarean delivery with labor vs. vaginal delivery | | | 1.66 (0.83; 3.32)
| Cesarean delivery without labor vs. vaginal delivery | | | 1.62 (0.81; 3.23)
Abramov, 2005 ^424^ | Cesarean only delivery | Fecal incontinence | | 0.39 (0.13; 1.04)
N = 346 | | Flatus | | 0.92 (0.52; 1.56)
Uustal Fornell, 2004 ^208^ | Cesarean section only | Anal incontinence | | 1.00 (1.00; 1.00)
N = 885
Bharucha, 2006 ^422^ | Cesarean section only, no surgery | Fecal incontinence | | 0.7 (0.3; 1.5)
N = 2,800
Richter, 2005 ^406^ | Number of cesarean deliveries | Anal incontinence | Morbid obesity before laparoscopic weight loss surgery | 0.84 (0.55; 1.29)
N = 180
Macarthur, 2005 ^404^ | Only caesarean section(s) | Fecal incontinence | 6 years postpartum | 1.04 (0.72; 1.50)
N = 4,046
Abramov, 2005 ^424^ | At least 1 episiotomy | Fecal incontinence | | 1.03 (0.45; 2.32)
N = 274 | | Flatus | | 1.22 (0.7; 2.11)
Eason, 2002 ^283^ | Episiotomy | Anal incontinence | 3 months postpartum | 1.1 (0.8; 1.4)
N = 252
Mazouni, 2005 ^228^ | Episiotomy | Fecal incontinence | 16 months instrumental delivery | 1.00 (1.00; 1.00)
N = 159
Hojberg, 2000 ^215^ | Episiotomy | Severity, isolated flatus incontinence at least once a week | At 16 weeks of gestation in the index-pregnancy | 1.9 (0.8′ 4.2)
Signorello, 2000 ^444^ | Episiotomy v 2nd/3rd/4th degree tear | Fecal incontinence | 3 months postpartum | 3.20 (1.30; 7.90)*
N = 626 | | | 6 months postpartum | 2.90 (0.70; 11.20)
| | Flatus | 3 months postpartum | 2.10 (1.30; 3.40)*
| | | 6 months postpartum | 2.10 (1.20; 3.70)*
| Episiotomy v intact/1st degree tear | Fecal incontinence | 3 months postpartum | 5.50 (1.80; 16.20)*
| | | 6 months postpartum | 3.70 (0.90; 15.60)
| | Flatus | 3 months postpartum | 1.70 (1.00; 2.80)
| | | 6 months postpartum | 2.30 (1.20; 4.30)*
De Leeuw, 2001 ^307^ | Mediolateral episiotomy, multiparity | Fecal incontinence | after anal sphincter damage during delivery | 1.25 (0.27; 5.83)
N = 250
Casey, 2005 ^367^ | Forceps delivery | Anal incontinence | Within 7 months of delivery, at or before their 6-month contraceptive follow up after delivery | 1.2 (0.5; 2.9)
N = 3,887
Eason, 2002 ^283^ | Forceps delivery | Anal incontinence | 3 months postpartum | 1.4 (1; 2.1)
N = 252
Guise, 2007 ^410^ | Forceps use, ever | severity, incontinence of stool | | 1.29 (0.98; 1.7)
N = 8,774
Abramov, 2005 ^424^ | At least 1 forceps delivery | Fecal incontinence | | 0.98 (0.4; 2.41)
N = 274 | | Flatus | | 0.76 (0.33; 1.21)
Frudinger, 2002 ^440^ | Forceps delivery | Anal incontinence | | 1.36 (0.35; 5.29)
N = 134
Sultan, 1993 ^445^ | Forceps delivery | Fecal incontinence | | 1.81 (0.12; 27.72)
N = 90
MacArthur, 2001 ^405^ | Forceps delivery | Fecal incontinence | 3 months postpartum | 1.94 (1.30; 2.89)*
N = 7,879
Sultan, 1993 ^445^ | Forceps delivery | Urgency | | 7.23 (0.85; 61.35)
N = 90 | Forceps delivery | Fecal incontinence and urgency | | 19.56 (1.12; 340.25)*
MacArthur, 2001 ^405^ | Forceps delivery | Frequent fecal incontinence | 3 months postpartum | 1.94 (1.07; 3.54)*
N = 7,879
Macarthur, 2005 ^404^ | Forceps deliver; n = 1,793 | Persistent fecal incontinence | 6 years postpartum among primiparae at index delivery. | 2.50 (1.37; 4.59)*
N = 4,046 | Forceps delivery; n = 3,813 | Persistent Fecal incontinence | 6 years postpartum | 2.06 (1.40; 3.04)*
Meyer, 2000 ^446^ | Forceps delivery vs. spontaneous delivery | Fecal incontinence | 10 month after delivery | 0.80 (0.75; 1.05)
N = 107
Schraffordt Koops, 2003 ^447^ | Forceps delivery vs. Spontaneous delivery | Fecal incontinence | incident 3–4 years after delivery | 1.25 (0.69; 2.27)
N = 479 | Forceps delivery vs. Spontaneous delivery | Fecal incontinence | 3–4 years after delivery | 0.80 (0.44; 1.44)
| Forceps delivery vs. Spontaneous delivery | Fecal incontinence Grade 2 | 3–4 years after delivery | 0.67 (0.22; 2.01)
| Forceps delivery vs. Spontaneous delivery | Fecal incontinence Grade 3 | 3–4 years after delivery | 1.23 (0.46; 3.30)
| Forceps delivery vs. Spontaneous delivery | Fecal incontinence Grade 4 | 3–4 years after delivery | 1.68 (0.74; 3.81)
Guise, 2007 ^410^ | Forceps use, this delivery | Severity, incontinence of stool | | 1.66 (1.1; 2.5)*
N = 8,774
Macarthur, 2005 ^404^ | ≥1 forceps deliveries | Fecal incontinence | 6 years postpartum | 1.48 (1.18; 1.87)*
N = 4,046
Hojberg, 2000 ^215^ | Outlet forceps | Severity, isolated flatus incontinence at least once a week | At 16 weeks of gestation in the index-pregnancy | 3.5 (0.4; 30.2)
Bharucha, 2006 ^422^ | Vaginal delivery with forceps or stitches, no surgery | Fecal incontinence | | 1.2 (0.9; 1.6)
N = 2,800
Mahony, 2007 ^448^ | Instrumental delivery | Fecal incontinence | | 3.10 (1.20; 7.90)*
N = 500
Liebling, 2004 ^25^ | Instrumental delivery vs. Cesarean | Pain on opening bowels | 6 weeks postpartum | 1.34 (0.74; 2.42)
N = 393 | | Constipation | 6 weeks postpartum | 0.85 (0.48; 1.49)
| | Increased passage of flatus | 6 weeks postpartum | 1.44 (0.87; 2.39)
| | Hemorrhoids | 6 weeks postpartum | 1.34 (0.80; 2.26)
| | Loss of control of bowels | 6 weeks postpartum | 1.25 (0.28; 5.63)
| | Pain on opening bowels | 1 year postpartum | 1.53 (0.44; 5.36)
| | Constipation | 1 year postpartum | 2.55 (1.02; 6.37)*
| | Increased passage of flatus | 1 year postpartum | 1.66 (0.88; 3.12)
| | Hemorrhoids | 1 year postpartum | 1.70 (0.92; 3.14)
| | Loss of control of bowels | 1 year postpartum | 1.74 (0.34; 8.87)
Faltin, 2001 ^328^ | Operative delivery | Anal incontinence | | 1.6 (0.9; 2.7)
N = 1,228 | Operative delivery | Fecal incontinence urgency | | 1 (0.5; 2.2)
Nichols, 2005 ^432^ | Operative delivery vs. vaginal delivery in stage II pelvic organ prolapse and/or urinary incontinence | Bothersome anal incontinence | | 4.50 (1.20; 17.10)*
N = 190
Nichols, 2004 ^449^ | Operative vaginal delivery | Anal incontinence | | 3.75 (1.60; 8.70)*
N = 100
Nichols, 2005 ^432^ | Operative vaginal delivery pelvic floor disorders vs. not operative delivery | Bothersome anal incontinence | | 3.60 (1.60; 8.80)*
N = 190
Faltin, 2006 ^442^ | Overactive vaginal delivery | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | 18 years after rupture of anal sphincter tear during childbirth | 1.83 (1.11; 3.02)*
N = 540
Hojberg, 2000 ^215^ | Oxytocin stimulation vs. stimulation | Severity, isolated flatus incontinence at least once a week | At 16 weeks of gestation in the index-pregnancy | 0.7 (0.4; 1.5)
Eason, 2002 ^283^ | % of days perineal massage performed <33 | Anal Incontinence | 3 months postpartum | 1 (1; 1)
N = 252 | % of days perineal massage performed ≥ 67 | | | 0.8 (0.6; 1.1)
| % of days perineal massage performed; 33– 66 | | | 1 (0.8; 1.3)
Abramov, 2005 ^424^ | At least 1 prolonged second stage of labor (>2 hrs) | Fecal incontinence | | 1.12 (0.49; 2.54)
N = 274 | | Flatus | | 1.04 (0.58; 1.78)
Mazouni, 2005 ^228^ | Length of labor 1 | Fecal incontinence | 15 months instrumental delivery | 1.00 (1.00; 1.00)
N = 159
Hojberg, 2000 ^215^ | Length of second stage ≤90 minutes | Severity, isolated flatus incontinence at least once a week | At 16 weeks of gestation in the index-pregnancy | 1 (1; 1)
| | | | 0.5 (0.1; 2.4)
Eason, 2002 ^283^ | Length of second stage of labor, ≥1.5 hour(vaginal delivery only) | Anal incontinence | 3 months postpartum | 0.9 (0.7; 1.2)
N = 252 | Length of second stage of labor, 0.5–0.9 hour(vaginal delivery only) | | | 0.8 (0.6; 1.2)
| Length of second stage of labor, 1–1.4 hour(vaginal delivery only) | | | 0.8 (0.6; 1.2)
Guise, 2007 ^410^ | Pushing time ever ≥1 hour | Severity, incontinence of stool | | 1.07 (0.91; 1.26)
N = 8,774
Frudinger, 2002 ^440^ | Second stage (hours) | Fecal incontinence | | 0.89 (0.57; 1.39)
N = 134
Casey, 2005 ^367^ | Second stage >2 hours vs. ≤2 hours | Fecal incontinence | Within 7 months of delivery, at or before their 6-month contraceptive follow up after delivery | 0.4 (0.2; 1.1)
N = 3,887
Uustal Fornell, 2004 ^208^ | Delivery by vacuum extractor | Flatus | | 1.40 (0.50; 4.50)
N = 885 | | Liquid | | 2.00 (0.70; 6.00)
| | Solid | | 1.20 (0.00; 7.50)
Schraffordt Koops, 2003 ^447^ | Vacuum extraction vs. Spontaneous delivery | Fecal incontinence Grade 4 | 3–4 years after delivery | 0.71 (0.29; 1.74)
N = 479
Eason, 2002 ^283^ | Vacuum delivery | Anal incontinence | 3 months postpartum | 1.3 (0.9; 1.8)
N = 252
Guise, 2007 ^410^ | Vacuum only, ever | Severity, incontinence of stool | | 1.12 (0.88; 1.42)
N = 8,774
MacArthur, 2001 ^405^ | Vacuum delivery | Fecal incontinence | 3 months postpartum | 1.26 (0.77; 2.07)
N = 7,879 | | Frequent fecal incontinence | 3 months postpartum | 1.29 (0.62; 2.71)
Macarthur, 2005 ^404^ | Vacuum delivery; n = 1,793 | Persistent Fecal incontinence | 6 years postpartum among primiparae at index delivery. | 0.41 (0.10; 1.75)
N = 4,046 | Vacuum delivery; n =3,813 | persistent Fecal incontinence | 6 years postpartum | 0.47 (0.15; 1.53)
Hojberg, 2000 ^215^ | Vacuum extraction | Severity, isolated flatus incontinence at least once a week | At 16 weeks of gestation in the index-pregnancy | 1.5 (0.6; 3.9)
Schraffordt Koops, 2003 ^447^ | Vacuum extraction vs. Spontaneous delivery | Fecal incontinence | Incident 3–4 years after delivery | 0.85 (0.48; 1.51)
N = 479 | | Fecal incontinence | 3–4 years after delivery | 1.18 (0.66; 2.09)
| | Fecal incontinence Grade 2 | 3–4 years after delivery | 0.97 (0.39; 2.41)
| | Fecal incontinence Grade 3 | 3–4 years after delivery | 0.97 (0.37; 2.52)
Guise, 2007 ^410^ | Vacuum only, this delivery | Severity, incontinence of stool | | 1.12 (0.82; 1.53)
N = 8,774
Peschers, 2003 ^450^ | Vacuum vs. spontaneous vaginal delivery | Anal incontinence | 6–24 weeks postpartum | 0.83 (0.36; 1.93)
N = 100 | | Fecal incontinence urgency | 6–24 weeks postpartum | 1 (0.236; 4.241)
| | Flatus incontinence >1/week | 6–24 weeks postpartum | 1.741 (0.393; 7.713)
| | Incontinence for liquid stood >1/week | 6–24 weeks postpartum | 7.442 (0.374; 147.925)
| | Incontinence for solid stool >1/week | 6–24 weeks postpartum | 3.061 (0.122; 76.949)
| | Flatus | 6–24 weeks postpartum | 1 (0.375; 2.664)
| | Liquid | 6–24 weeks postpartum | 1 (0.236; 4.241)
| | Solid | 6–24 weeks postpartum | 3.128 (0.314; 31.142)
| | Fecal incontinence soiling | 6–24 weeks postpartum | 0.683 (0.201; 2.315)
Faltin, 2006 ^442^ | Non operative vaginal delivery | Severity, at least 2 symptoms at least once a week or 3 symptoms (symptoms: incontinence to flatus, liquid or solid stool; need to wear a pad; lifestyle alteration) | 18 years after rupture of anal sphincter tear during childbirth | 1 (1; 1)
N = 540
De Leeuw, 2001 ^307^ | Subsequent vaginal delivery | Fecal incontinence | After anal sphincter damage during delivery | 2.32 (0.85; 6.33)
N = 250
Boreham, 2005 ^331^ | Vaginal parity (per delivery) | Anal incontinence | | 1.16 (1; 1.35)
N = 457
Borello-France, 2006 ^451^ | Vaginal control | Fecal incontinence | 6 weeks postpartum | 1.1 (0.49; 2.5)
N = 472 | | Fecal incontinence | 6 months postpartum | 1.01 (0.38; 2.71)
| | Fecal incontinence urgency | 6 weeks postpartum | 0.67 (0.39; 1.13)
| | Fecal incontinence urgency | 6 months postpartum | 0.53 (0.29; 0.93)
| | Flatus | 6 weeks postpartum | 1.3 (0.67; 2.6)
| | Flatus | 6 months postpartum | 0.48 (0.24; 0.96)
Ng, 2002 ^408^ | Vaginal delivery | Anal incontinence | | 1.09 (0.34; 1.25)
N = 320
Chen, 2003 ^284^ | Vaginal delivery | Anal incontinence | | 1.1 (0.8; 1.5)
N = 1,253
Uustal Fornell, 2004 ^208^ | Vaginal delivery | Flatus | | 1.10 (0.40; 3.00)
N = 885 | | Flatus | | 1.50 (0.80; 2.70)
| | Liquid | | 0.80 (0.30; 2.10)
| | Liquid | | 1.00 (0.50; 1.80)
| | Solid | | 1.00 (0.30; 2.70)
Bharucha, 2006 ^422^ | Vaginal delivery without forceps or stitches, no surgery | Fecal incontinence | | 0.8 (0.5; 1.1)
N = 2,800
MacLennan, 2000 ^84^ | Vaginal vs. Caesarean delivery | Fecal incontinence | | 1.50 (0.50; 4.90)
N = 3,010 | | Flatus | | 1.80 (0.80; 3.80)
Melville, 2005 ^338^ | H/O operative vaginal delivery | Fecal incontinence | | 1.52 (1.09; 2.12)*
N = 6,888 | Mixed/unknown delivery types | Fecal incontinence | | 1.44 (0.82; 2.54)

Bold = multivariate odds ratios

* Significant difference

Evidence Tables — Clinical Interventions to Reduce Risk of Incidence and Progression of Urinary Incontinence in Adults

Clinical Interventions on Urinary Incontinence in Adults in Long-term Care Settings and Nursing Homes

Table F58 Effects of implementation of evidence based guidelines on urinary incontinence in residents of nursing homes

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Ryden, 2000 ^452^ | Consecutive cohorts of newly admitted residents in 3 licensed proprietary nursing homes certified for Medicare, located in the suburban area comparable by occupancy rates, staff-to-resident ratios, staff turnover, resident acuity, and percentage of residents whose medical care was monitored by external nurse practitioners employed by physician group practices or managed care groups with 201–262 beds. | 1 Implementation of evidence-based protocol by advanced practice gerontological nurses: in-service staff education and direct resident care.; 2 Usual care by nursing home staff. | Urinary incontinence recorded by nursing home staff in Incontinence monitoring schedule: observations every 2 hours, 24 hours a day for 3 days; percentage of wetness 5; average number of times wet per day for the 3-day period. | No intention to treat. Open label.
Quasi-experimental RCT to examine the effect of scientifically based protocols implemented by advanced practice gerontological nurses for incontinence in nursing home residents | Loss of followup: 86 treatment residents (2.4% withdrew, 18.0% were discharged, and 27.5% died) and 111 comparison group residents (2.0% withdrew, 9.2% were discharged, and 16.3% died). | | | Allocation concealment unclear. Baseline data confirmed adequacy of randomization. No justification for sample size.
Duration: 6 months
Schnelle, 1995 ^453^ | 9 nursing homes, members of state long-term care association location within 1.5 hours driving distance from one another, agree to train staff. | Gradual implementation of computerized quality management model based on the federal guidelines for medical assessment and individualized prompted voiding protocols of incontinence. | % of wet residents collected using random hour wet check procedure by independent research assistants with nursing home experience | No intention to treat. Not randomized.
Multicenter non controlled intervention to examine computerized total quality management model for implementation of incontinence system in nursing homes. | Exclusion criteria: not representative staffing rates and resident mix compared to nursing homes in the area. | | | Implementation of quality management model with before-after comparisons.
Duration: 6 months. | | | | No justification for sample size.

Table F59 Comparative effectiveness of implementation of evidence-based guidelines on urinary incontinence in residents of nursing homes

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Ryden, 2000 ^452^ | Implementation of evidence-based protocol by advanced practice gerontological nurses: in-service staff education and direct resident care. | Usual care by nursing home staff | % of times wet recorded by nurse | 35 | 40 | 21.0 | 26.0 | 0.8 (0.5; 1.2)
N = 319 | | | % of residents with Improvement in incontinence recorded by nurse | 78 | 66 | 47.0 | 43.0 | 1.1 (0.9; 1.4)
71% female | | | Incontinence prevalence reported by a nurse | 106 | 108 | 63.9 | 70.6 | 0.9 (0.8; 1.1)
Schnelle, 1995 ^453^ | After gradual implementation of computerized quality management model for medical assessment and individualized prompted voiding protocols of incontinence | Before gradual implementation of computerized quality management model for medical assessment and individualized prompted voiding protocols of incontinence | % of wet residents | 14 | 26 | 17.0 | 31.0 | 0.5 (0.3; 1.0) | 7 (5; 77) | 140 (216; 13)A
N = 85

Table F60 Effects of conservative management programs on urinary incontinence in females, residents of nursing homes

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Hu, 1990 ^454^ | 133 incontinent elderly females in seven nursing homes, ages 65 or over, incontinent during the daytime, and able to recognize their own name. | 1 Behavioral therapy program for 3 months implemented by project-trained NRAs. With hourly wet checks, prompted and assisted toileting, positive reinforcement, bladder training to hold urine until the next hourly check.; 2 Usual care. | Reported by nurses participants' wet episodes and patient requests for toileting. | No intention to treat. Open label.
RCT to examine the effects of behavioral training therapy on incontinent elderly in nursing homes. | Exclusion criteria: not reported. | | | Randomization and allocation concealment not reported. Baseline data did not confirm adequacy of randomization.
Duration: 3 months, followup: 22 weeks. | Loss of followup: 7%. | | | Sample size justified
Hu, 1989 ^455^ | 143 women with confirmed stress incontinence in seven nursing homes with ability to recognize her own name. | 1 13-week behavior therapy program for urinary incontinence which included hourly checking and prompting of individuals to toilet, praising for successful toileting, and social reinforcement (additional personal service). Assisted toileting between scheduled voiding. The program was implemented 14 hours/day, 7 days/week for 3 months.; 2 Control group received usual incontinence-related care. | The change in urinary stress incontinence measured by the RN as wet checks/total checks/day (14 times/day). | No intention to treat. Open label.
RCT to examine the effects of behavior therapy program for urinary incontinence on women residents of nursing homes. | Exclusion criteria: hospitalization, insufficient number of wet episodes per day (an average 0.18). | | | Randomization schedule not reported. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
Duration: 3 months. | Loss of followup: 6.9%
Ouslander, 2001 ^456^ | 32 incontinent female residents (average age 88) from 5 nursing homes. Incontinence was diagnosed by nursing home staff and research staff using checks for wetness as involuntary loss of urine at least daily. | 1 Oral estrogen (0.625mg) combined with progesterone (2.5mg) and regular toileting assistance (prompted voiding) by trained research aides during 3-day data-collection periods; 2 Placebo and regular toileting assistance (prompted voiding) by trained research aides during 3-day data-collection periods | The frequency of urinary incontinence as wetness rate = the percentage of checks at which research staff found residents to be wet during three 8-hour days of prompted voiding. The appropriate toileting rate was calculated by dividing the number of continent voids by the total number of voids. | No Intention to treat. Open label.
RCT to examine the effects of oral estrogen/progestin on incontinence in female nursing home residents. | Exclusion criteria: Medicare reimbursement (indicating a potential short stay and/or medical instability), terminal illness, cognitive impairment; history of breast or cervical cancer; wet <1/day on research staff checks; enteral feeding; poor cooperation with screening procedures; severe physical immobility, requiring a lift or 3-person transfer. | | Cough tests for stress incontinence as positive (simultaneous leakage with cough), negative with estimated bladder volumes of at least 100ml (determined by voided volume plus residual bladder volume by ultrasound), negative, or unable to perform (some subjects would not cough on command). | Central randomization with table of random numbers. Allocation concealment not adequate.
Duration 6 months | Loss of follow up: 34% | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.

Table F61 Comparative effectiveness of conservative management programs on urinary incontinence in females, residents of nursing homes (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Hu, 1990 ^454^ | Behavioral therapy program for 3 months implemented by the project-trained NRAs. | Usual care | % improvement in urinary incontinence reported by nursing home staff | 19 | 6 | 26.0 | 8.0 | 3.1 (1.3; 7.4) | 6 (2; 38) | 180 (26; 509)E
N = 143 | | | 75–99% improvement in urinary incontinence reported by nursing home staff | 4 | 3 | 5.0 | 4.0 | 1.3 (0.3; 5.7)
Ouslander, 2001 ^456^ | Oral estrogen (0.625 mg) combined with progesterone (2.5 mg) and regular toileting assistance (prompted voiding) by trained research aides during 3-day data-collection periods | Placebo and regular toileting assistance (prompted voiding) by trained research aides during 3-day data-collection periods | Positive cough test | 0 | 3 | 0 | 17.6 | 0.16 (0.01; 2.88)
N = 32

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome inn1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F62 Comparative effectiveness of conservative management programs on urinary incontinence in 143 females, residents of nursing homes

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Baseline (95% CI)
Hu, 1989 ^455^ | Behavioral therapy program for 3 months implemented by the project-trained registered nurses | Usual care | Urinary wet episodes/day reported by nursing home staff | 1.7 ± 1.8 | 1.9 ± 1.3 | -0.2 (-0.5; 0.2) | -9.0 (-26.3; 8.3)
| 13-week behavior therapy program for urinary incontinence | Usual incontinence-related care | Number of incontinence episodes/day | 2.2 ± 1.3 | 2.1 ± 1.1 | 0.1 (-0.2; 0.5) | 6.0 (-9.9; 21.9)
Ouslander, 2001 ^456^ | Oral estrogen (0.625 mg) combined with progesterone (2.5 mg) and regular toileting assistance (prompted voiding) by trained research aides during 3-day data-collection periods | Placebo and regular toileting assistance (prompted voiding) by trained research aides during 3-day data-collection periods | Appropriate toileting rate, % of continent voids by the total number of voids | 37 ± 31 | 31 ± 29 | 0.20 (-0.50; 0.90) | 0.20 (0.36; -0.50)
N = 32

Table F63 Effects of conservative management programs on urinary incontinence in residents of nursing homes

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Schnelle, 1989 ^457^ | 126 incontinent patients from proprietary nursing homes (bed size 90–150), not affiliated with universities with correct discriminatory responses to instructions to point to shown subjects (pencil or glass). | 1 Prompted voiding treatment: check for incontinence, asking for needed toileting assistance, prompted voiding, and socially reinforced for appropriate toileting.; 2 Usual care. | Urinary incontinence measured by nurse as wet checks/total checks and daily percent of appropriate toileting equal number of times the patient voided in any toilet receptacle/total number of appropriate and incontinent voiding. | No intention to treat.
RCT to examine the effects of prompted voiding treatment of urinary incontinence in nursing home patients. | Exclusion criteria: continence, transfer to hospital during run-in period. | | | Open label.
Duration: 5–10 days. | Loss of followup: 60% during the run-in period, 2.4% after randomization. | | | Randomization and allocation concealment unclear.
| | | | Baseline data not reported. Sample size not justified.
Ouslander, 2005 ^458^ | 107 patients in nursing homes, (resided in the facility at least 30 days and not initially admitted for short-term care; able to state their name, or in the presence of aphasia, capable of reliably pointing to two objects; required assistance by two or fewer people for transfer from bed to chair; with life expectancy of at least 6 months; not receiving active physical therapy; and ages 60 and older. | 1 Functional incidental training: prompted voiding combined with individualized, functionally oriented endurance and strength-training exercises offered 4 times/day, 5 days/week.; 2 Usual care. | Urinary and fecal incontinence measured as wet checks/total checks of the participants every 2 hours. Appropriate toileting rate: number of voids or bowel movements that were continent divided by the total number of voids or bowel movements. | No intention to treat.
Crossover RCT to examine the effects of functional incidental training on incontinence in nursing homes. | Exclusion criteria: continence, severe behavioral changes, terminally ill. | | | Open label.
Duration: 8 weeks. | Loss of followup: 60%. | | | Computer-generated random numbers.
| | | | Allocation concealment unclear.
| | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Schnelle, 2002 ^459^ | 256 incontinent residents in 4 nursing homes. | 1 Integrated incontinence care and exercise every 2 hours 5 days a week including fluid prompting, prompted toileting, and regular wet checks, arm raise and arm curl exercises.; 2 Usual care. | Fecal and urinary incontinence frequency as % of hourly wet checks and the appropriate toileting ratio calculated by dividing the number of times a resident used a toilet or toilet substitute by the total number of voids. | No intention to treat.
RCT to examine the effects of integrated incontinence care and exercise on urinary incontinence in nursing home residents. | Exclusion criteria: post-acute skilled care units, terminally ill. | | | Single blind.
Duration: 8 months. | Loss of followup: 26%. | | | Computerized randomization.
| | | | Allocation concealment unclear.
| | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Jirovec, 2001 ^460^ | 118 caregivers for incontinent, memory-impaired elders. | 1 Individualized scheduled toileting procedure of every 2 hours and fluid intake ~six 8-oz glasses/day provided by trained caregivers.; 2 Usual care. | Incontinence calculated as the percentage of time the patient was incontinent by dividing the incontinent episodes by the total number of voiding episodes, both continent and incontinent. | No Intention to treat, Open label.
RCT to examine the effects of individualized scheduled toileting program on incontinent, memory-impaired elders being cared for at home. | Exclusion criteria: fecal continence. | | | Randomization using the table of random numbers. Allocation concealment unclear.
Duration: 6 months. | Loss of followup: 16.9% during implementation and 37% during 6 months period. | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Colling, 1992 ^461^ | 113 elderly subjects, 65 years and older with >3 episodes of clinical and urodynamic urinary incontinence/week for the last 12 weeks, cognitively and/or physically impaired, residents of 4 non-profit urban nursing homes with bed size 120–342. | 1 Individualized form of habit training for urinary incontinence administered by trained staff: toileting within 30 minutes prior to the mean time of voids within 1 hour block of time. Verbal encouragement to nursing staff to comply with the program.; 2 Usual care. | Episodes of urinary incontinence/day measured by nursing staff. Wet checks were done hourly for one 24-hour period at 3-week intervals. Continuous electronic monitoring of voids for precise voiding schedule for each subject. | No intention to treat.
Quasi-experimental RCT to examine the effects of individualized form of habit training for urinary incontinence among elderly nursing homes residents. | Exclusion criteria: toilet with assistance of more than1 staff member, fecal impaction, rectal or pelvic mass, prostate diseases, severe prolapse, atrophic vaginitis, neurological diseases, post-residual volume >200ml. | | | Open label.
Duration: 12-week intervention and 12 week followup. | Loss of followup: 21% | | | Randomization at unit level. Allocation concealment unclear.
| | | | Baseline data differed by the proportion of males and length of stay. Sample size justified.

Table F64 Comparative effectiveness of conservative management programs on urinary incontinence in residents of nursing homes (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Colling, 1992 ^461^ | Individualized form of habit training for urinary incontinence administered by trained staff: toileting within 30 minutes prior to the mean time of voids within 1 hour block of time. | Usual care | Incontinent volume of urine loss, ml | 500.0 ± 450.0 | 600.0 ± 400.0 | -0.2 (-0.6; 0.1) | 0.0 (-0.1; 0.0)
N = 113 | Verbal encouragement to nursing staff to comply with the program.
66% female
Schnelle, 2002 ^459^ | Integrated incontinence care and exercise every 2 hours 5 days a week including fluid prompting, prompted toileting, and regular wet checks, arm raise and arm curl exercises | Usual care | Urinary incontinence frequency, % of wet checks | 23.0 ± 21.0 | 35.0 ± 21.0 | -0.6 (-0.9; -0.3) | -1.6 (-2.5; -0.8)
N = 190
84% female
Schnelle, 1989 ^457^ | Prompted voiding treatment: check for incontinence, asking for needed toileting assistance, prompted voiding, and socially reinforced for appropriate toileting | Usual care | Percent appropriate toileting | 59.4 ± 26.7 | 16.8 ± 22.0 | 1.7 (1.3; 2.2) | 10.4 (7.9; 12.8)
N = 126 | | | Percent wet checks/total checks, % | 17.8 ± 13.0 | 34.5 ± 16.8 | -1.1 (-1.5; -0.7) | -3.2 (-4.3; -2.1)
75% female
Colling, 1992 ^461^ | Individualized form of habit training for urinary incontinence administered by trained staff: toileting within 30 minutes prior to the mean time of voids within 1 hour block of time. | Usual care | Urinary incontinence episodes/day (wet checks) | 3.9 ± 1.0 | 4.8 ± 1.0 | -0.9 (-1.3; -0.5) | -18.8 (-26.9; -10.6)
N = 113 | Verbal encouragement to nursing staff to comply with the program.
66% female
Ouslander, 2005 ^458^ | Functional Incidental training: prompted voiding combined with individualized, functionally oriented endurance and strength-training exercises offered 4 times/day, 5 days/week | Usual care | Change after the treatments in wet checks/total checks, % | | | -17 (-83.9; 49.9)
N = 107 | | | Wet checks/total checks, % | 25.0 ± 50.0 | 50.0 ± 28.0 | -0.6 (-1.0; -0.2) | -1.2 (-2.0; -0.5)
10% female
Jirovec, 2001 ^460^ | Individualized scheduled toileting procedure of every 2 hours and fluid intake ~six 8-oz glasses/day provided by trained caregivers. | Usual care | % of urinary incontinent episodes/total voids | 37.0 ± 28.0 | 49.0 ± 36.0 | -0.4 (-0.7; 0.0) | -0.8 (-1.5; 0.0)
N = 118
30% female

Bold- significant differences in outcomes at 95% confidence level

Table F65 Effects of conservative management programs on urinary incontinence in patients admitted for rehabilitation following acute unilateral hemispheric stroke

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Wikander, 1998 ^462^ | 34 incontinent stroke patients admitted for rehabilitation following acute unilateral hemispheric stroke. | 1 Specially designed education for ward staff based on the Functional Independence Measure Scale and for patients to manage incontinence independently.; 2 Conventional method inhibiting abnormal muscle tone by handling and guiding the stroke patient in specific ways to relearn normal movements, which makes the patient dependent on ward staff for a longer period of time. | Urinary incontinence and the need for assistance because of urinary incontinence assessed by the staff with FIM-G (7-point scale, 7 - independent – 1 - totally dependent | Intention to treat not stated but all patients were included in the analysis. Open label. Allocation concealment not adequate, patients were randomly allocated to one of two different wards depending on the availability of beds on the day of admission.
RCT to examine the effects of rehabilitation governed by functional independence measure on urinary incontinence in patients with acute hemispheric stroke Duration: Length of stay in the ward (~90 days) | Exclusion criteria: not reported. | | | Baseline data confirmed adequacy of randomization. No justification for sample size.
| Lost of followup: none

Table F66 Comparative effectiveness of conservative management programs on urinary incontinence in patients admitted for rehabilitation following acute unilateral hemispheric stroke

Author | Outcome | Active Treatment | Control Treatment | Number of Case After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Wikander, 1998 ^462^ | Number cured at discharge | Specially designed rehabilitation program to increase patient independent management of UI | Conventional rehabilitation program (patient dependent on ward staff for a longer period of time). | 20 | 3 | 95.2 | 23.1 | 4.1 (1.5; 11.2) | 1 (0; 8) | 722 (121; 2,350)E
N = 34 | Number discharged to a nursing home due to incontinence | | | 2 | 8 | 9.5 | 61.5 | 0.2 (0.0; 0.6) | 2 (2; 4) | 520 (234; 592)A
56% female

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome inn1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Clinical Interventions on Urinary Incontinence in Adults in the Community

Table F67 Effects of implementation of evidence based guidelines on urinary incontinence in adults

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Chadha, 2000 ^463^ | 449 women with urinary incontinence from gynecology units in four district general hospitals across Scotland. | National evidence based guidelines adapted locally to protocols, which were disseminated at specific local educational meetings and implemented by placing a copy of the appropriate protocol in women's hospital case notes prior to consultation. | Self reported perception of urinary incontinence based on questions routinely asked by clinicians. | No intention to treat.
RCT to examine the effects of national guidelines and local protocols in improving hospital care for women with UI. | Exclusion criteria: not reported. | | | Randomization stratified by hospital size and location. 2 × 2 balanced incomplete block controlled before and after study.
Duration: 12 months | Loss of followup: 7.6% | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size justified for process of care outcomes.

Table F68 Comparative effectiveness of evidence based guidelines on urinary incontinence in adults, self reported severity and impact of urinary incontinence

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Chadha, 2000 ^463^ | National evidence based guidelines adapted locally to protocols, which were disseminated at specific local educational meetings and implemented by placing a copy of the appropriate protocol in women's hospital case notes prior to consultation. | Pre-guidelines levels | Self-reported perception of urinary incontinence, scores | 15.5 ± 20.3 | 13.9 ± 20.7 | 0.1 (-0.1; 0.2) | 0.6 (-0.4; 1.5)
N = 449
100% female

Table F69 Effects of conservative management programs on urinary incontinence in community-dwelling adults

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Williams, 2005 ^464^ | 3,746 men and women ages 40 years and over living in private households reporting incontinence several times per month or more, or several times a year and reported significant impact of symptoms on quality of life. | 1 Continence service that included advice on diet and fluids; bladder training; pelvic floor awareness and lifestyle advice.; 2 Existing primary care including GP and continence advisory services in the area. | Self-reported in validated questionnaire improvement or cure in one or more symptoms of total incontinence, urgency, frequency and nocturia. | Intention to treat. Open label.
RCT to examine the effects of continence service provided by specially trained nurses delivering evidence-based interventions using predetermined care pathways in adults. | Exclusion criteria: pregnancy, urinary fistula, pelvic malignancy, treatment for urinary symptoms. | | | Randomization by household, at a ratio of 4:1 in favor of the continence nurse practitioner. Allocation concealment and randomization adequate.
Duration: 6 months | Loss of followup: 37% refused followup at 3 months, 22% refused followup at 6 months. | | | Sample size justified.
Borrie, 2002 ^465^ | 421 subjects 26 years of age or older with self reported urinary incontinence at least once per week, resided in the community, and communicated in English. | 1 Lifestyle modification sessions every 4 weeks led by trained “nurse continence advisers” with a physician with expertise in continence management.; 2 Usual care | Self reported urinary incontinent events (measured using bladder diaries) and pad use (measured using the questionnaire) per 24 hours | Intention to treat. Open label. Computer generated randomization with random permuted blocks, block size of 4. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. No justification for sample size.
RCT to examine the effects of combined lifestyle and behavioral interventions led by nurses in the management of urinary incontinence. | Exclusion criteria: pregnancy, residency of long-term care institutions, dementia.
Duration: 6 months | Loss of followup: 10.1%
Dowd, 2000 ^466^ | 40 subjects >40 years of age, independent in self-care, with history of incontinence and/or frequency for at least 6 months, able to read and write English, and having hearing adequate for listening to an audiotape. | 1 Education about bladder health, recorded incontinence and frequency episodes in a voiding diary, and listening to the audiotape daily.; 2 Education about bladder health and recorded incontinence and frequency episodes in the voiding diary | Comfort measured with the Urinary Incontinence and Frequency Comfort Questionnaire (UIFCQ) - 23 positive and negative items ranging from strongly agree to strongly disagree scored from 1 to 6 - higher comfort. The number of incontinent episodes and frequency of toileting recorded in a voiding diary with scores 8–96 incontinent episodes and 50–125 frequency episodes per week. | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of cognitive strategies combined with educational programs in urinary incontinence. | Exclusion criteria: presence of urinary tract infections or severe neurological disorders.
Duration: 6 weeks | Loss of followup: not reported
Moore, 2003 ^467^ | 145 consecutive patients with stress and/or urge incontinence with idiopathic detrusor instability, sensory urgency, and mild or moderate leakage (urine loss in 1-hour pad test 2–9.9ml/hour or 10– 50ml/hour). | 1 2 nurse continence advisors/patient and consulting urogynecologist for 25–35 minutes/week provided bladder training, gradual increase in fluid intake, individual deferment techniques, pelvic floor muscle exercise and examination, transvaginal electrostimulation.; 2 Outpatient regimen with 15– 20 minute consultation with referral to physiotherapist and bladder training. | 1-hour pad test, frequency volume charts, a 20-point incontinence score, and two quality of life tests (Incontinence Impact Questionnaire and Urogenital Distress Inventory). Objective cure as dry on 1-hour pad test. Subjective cure as >50% benefit on pad test but the patient felt cured and ready for discharge | Intention to treat. Open label.
RCT to examine the effects of nurse continence advisors and urogynaecologists in conservative management of urinary incontinence. Duration: 12 weeks | Exclusion criteria: previous pelvic radiotherapy, proven recurrent bacterial cystitis, prolapse beyond the introitus, uterine enlargement or incomplete bladder emptying (postvoid residual >100ml). | | | Computer-generated randomization stratified with respect to mild and moderate leakage with permuted blocks of 20. Allocation concealment not adequate.
| Loss of followup: 22% | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
McFall, 2000 ^468^ , ^469^ | 145 women ages 65 or older with self reported urinary incontinence ≥ 3 months, residing in Oklahoma. | 1 Community-based intervention with 5 biweekly sessions of education and skill-building, for bladder training, managing the urge to urinate, and performing pelvic muscle exercises. Group support by registered nurses; occupational therapist, and public health educator.; 2 Usual care | Self reported episodes of incontinence and frequency of voluntary micturition (voiding) per week. | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. No justification for sample size.
RCT to examine the effects of community-based intervention on self-management of urinary incontinence in elderly women | Exclusion criteria: Severe prolapse of uterus, hematuria, diverticulum, fistula, unresolved urinary tract infection, two or more urinary tract infections within 3 months, urinary obstruction, overflow incontinence, a postvoid residual volume of urine (PVR) >100ml, and blood glucose >300 mg/dl on two or more visits in a 3 month period, functional disability, severe hearing or vision problems, low literacy, and cognitive impairment.
Duration: 3 months | Loss of followup: 8.3%

Table F70 Comparative effectiveness of conservative management programs on urinary incontinence in adults (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Active Cases | Number of Control Cases | % Active | % Control | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Williams, 2005 ^464^ | Continence service that included advice on diet and fluids; bladder training; pelvic floor awareness and lifestyle advice | Existing primary care including GP and continence advisory services in the area | % of mild urinary incontinence or no problem with urine leakage | 2,337 | 552 | 79.0 | 70.0 | 1.1 (1.1; 1.2) | 11 (8; 19) | 90 (52; 129)E
N = 3,746 | | | % satisfied with current urinary symptoms for rest of life | 1,893 | 418 | 64.0 | 53.0 | 1.2 (1.1; 1.3) | 9 (6; 15) | 110 (66; 156)E
60% female | | | % cured | 828 | 150 | 28.0 | 19.0 | 1.5 (1.3; 1.7) | 11 (7; 20) | 90 (49; 136)E
| | | Frequency (≥once hourly) | 710 | 260 | 24.0 | 33.0 | 0.7 (0.6; 0.8) | 11 (9; 17) | 90 (117; 60)A
| | | Improvement | 1,834 | 410 | 62.0 | 52.0 | 1.2 (1.1; 1.3) | 10 (7; 18) | 100 (56; 146)E
| | | Leakage (several times/month) | 1,804 | 512 | 61.0 | 65.0 | 0.9 (0.9; 1.0)
| | | Nocturia (≥3 times/night) | 562 | 189 | 19.0 | 24.0 | 0.8 (0.7; 0.9) | 20 (13; 49) | 50 (20; 76)A
| | | Urgency: very strong or overwhelming | 917 | 331 | 31.0 | 42.0 | 0.7 (0.7; 0.8) | 9 (7; 13) | 110 (78; 139)A

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome inn1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events= 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F71 Comparative effectiveness of combined conservative management programs on urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Active Cases | Number of Control Cases | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI)
Sample
Moore, 2003 ^467^ | 2 nurse continence advisors/patient and consulting urogynecologist for 25– 35 minutes/week provided bladder training, gradual increase in fluid intake, individual deferment techniques, pelvic floor muscle exercise and examination, transvaginal electro stimuli. | Out patient regimen with 15–20 minute consultation with referral to physiotherapist and bladder training. | Objective cure as dry on 1-hour pad test | 37 | 27 | 50.0 | 38.0 | 1.3 (0.9; 1.9)
N = 145
McFall, 2000 ^468^ | Community-based intervention: bladder training, managing the urge to urinate, and performing pelvic muscle exercises. | Usual care | Self reported urinary continence (100% improvement) | 25 | 15 | 35.0 | 20.0 | 1.7 (1.0; 2.9)
N = 145 | | | Self reported Improvement in urinary incontinence of 50% or greater | 44 | 28 | 61.0 | 38.0 | 1.6 (1.1; 2.2) | 4 (2; 20)E

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F72 Comparative effectiveness of combined conservative management programs on urinary incontinence in females, self reported severity and impact on life

Author | Active Treatment | Control Treatment | Outcome | Mean ± After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Baseline (95% CI)
Sample
Moore, 2003 ^467^ | 2 nurse continence advisors/patient and consulting urogynecologist for 25– 35 minutes/week provided bladder training, gradual increase in fluid intake, individual deferment techniques, pelvic floor muscle exercise and examination, and trans vaginal electrostimulation | Out patient regimen with 15–20 minutes consultation with referral to physiotherapist and bladder training. | Incontinence score | 4.0 ± 1.8 | 3.0 ± 2.0 | 0.5 (0.2; 0.9) | 17.4 (6.4; 28.4)
N = 145 | | | Voids/day | 6.0 ± 0.7 | 6.0 ± 0.7 | 0.0 (-0.3; 0.3) | 0.0 (-5.4; 5.4)
| | | Voids/night | 1.0 ± 0.0 | 1.0 ± 0.0
| | | Pads/day | 1.0 ± 0.0 | 1.0 ± 0.7
| | | Quality of life urogenital distress inventory | 18.0 ± 6.2 | 15.5 ± 5.0 | 0.4 (0.1; 0.8) | 2.9 (0.7; 5.0)
| | | Short urogenital distress inventory 16 | 8.0 ± 1.5 | 6.0 ± 2.5 | 1.0 (0.6; 1.3) | 16.2 (10.5; 22.0)
| | | Quality of life incontinence impact questionnaire | 36.0 ± 9.3 | 37.5 ± 3.7 | -0.2 (-0.5; 0.1) | -0.6 (-1.4; 0.3)
| | | Short incontinence impact questionnaire 7 | 11.0 ± 1.3 | 10.0 ± 2.3 | 0.5 (0.2; 0.9) | 5.3 (2.0; 8.6)
| | | Leaks/week | 3.0 ± 4.7 | 2.5 ± 3.0 | 0.1 (-0.2; 0.5) | 5.1 (-8.0; 18.1)
| | | Pad test (ml) | 2.0 ± 4.2 | 2.0 ± 4.0 | 0.0 (-0.3; 0.3) | 0.0 (-16.3; 16.3)
McFall, 2000 ^468^ | Community-based intervention: bladder training, managing the urge to urinate, and performing pelvic muscle exercises | Usual care | Self reported number of urinary incontinent episodes/week | 3.6 ± 7.2 | 5.9 ± 8.5 | -0.3 (-0.6; 0.0) | -5.1 (-10.6; 0.5)
N = 145 | | | Nocturnal micturition | 9.9 ± 9.3 | 9.6 ± 5.9 | 0.0 (-0.3; 0.4) | 0.4 (-3.0; 3.8)

Bold- significant differences in outcomes at 95% confidence level

Table F73 Comparative effectiveness of conservative management programs on urinary incontinence in adults, self reported severity and quality of life

Author | Active Treatment | Control Treatment | Outcomes | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Baseline (95% CI)
Sample
Borrie, 2002 ^465^ | Lifestyle modification sessions every 4 weeks led by trained “nurse continence advisers” | Usual care | Change in pad use for urinary incontinence events from baseline | -0.9 ± 4.4 | -0.1 ± 3.7 | -0.2 (-0.4; 0.0) | 195.8 (4.3; 387.3)
N = 446 | | | Change in urinary incontinence events from baseline | -1.2 ± 3.0 | -0.2 ± 3.0 | -0.3 (-0.5; -0.1) | 168.9 (72.7; 265.1)
73% female

Bold- significant differences in outcomes at 95% confidence level

Table F74 Comparative effectiveness of educational intervention on urinary incontinence in adults (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Active Cases | Number of Control Cases | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Dowd, 2000 ^466^ | Education about bladder health, recorded incontinence and frequency episodes in a voiding diary, and listening to the audiotape daily | Education about bladder health and recorded incontinence and frequency episodes in the voiding diary | Improvement in the number of incontinent episodes and frequency of toileting | 18.9 | 9.88 | 90.0 | 52.0 | 1.7 (1.1; 2.7) | 3 (1; 20) | 380 (51; 880)E
N = 40 | | | Improvement in Urinary Incontinence and Frequency Comfort Questionnaire | 18.9 | 12.7 | 90.0 | 67.0 | 1.3 (0.9; 1.8)
74% female

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F75 Effects of dietary and other lifestyle interventions on risk and progression of urinary incontinence in adults

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Subak, 2005 ^470^ | 48 women 18 to 80 years old with body mass index between 25 and 45 kg/m2, urinary incontinence for at least 3 months and at least 4 incontinent episodes/week, the stable dose of other incontinence therapy. | Weight reduction intervention: 3-month standard low calorie liquid diet (800kcals/day or less), increased physical activity to 60 minutes/day, training by a nutritionist, exercise physiologist or behavioral therapist | A 7-day voiding diary to report frequency of voids and incontinent episodes classified by clinical type (urge, stress, other). Urodynamic outcomes. | Intention to treat. Single blind (investigators assessing outcomes and statistical analysts).
RCT to examine the effect of weight loss on urinary incontinence in overweight and obese women. | Exclusion criteria: pregnancy, urinary tract infection, significant medical condition, pelvic cancer, neurological condition possibly associated with incontinence, interstitial cystitis or potential inability to complete the study. | 1 Immediate intervention group; 2 Delayed for 3 month intervention | | Randomization was stratified by type of incontinence, with randomly permuted blocks of 4. Allocation concealment adequate.
Duration: 3 months | Lost of followup: 4 women; 1 withdrew from the study, 1 dropped due to medical condition, 2 had missing primary outcome data. | | | Baseline data confirmed adequacy of randomization. Sample size justified.
Dowd, 1996 ^471^ | 58 women 50 years old and older with incontinence more than 6 months, independent in self-care, English speakers with >20 scores on Mini-Mental State. | 1 Increase fluid intake by 500cc; 2 Maintain fluid intake at baseline level; 3 Decrease by 300cc | Self reported episodes of urinary incontinence per week | No intention to treat. Open label. Allocation concealment unclear.
RCT to examine the effects of hydration on the number of urinary incontinence episodes. | Exclusion criteria: not provided. | | | Baseline data not provided but some differences at baseline reported. No justification of the sample size.
Duration: 5 weeks | Lost of followup: Not reported, 32 women maintained diaries and included in the analysis.
Swithinbank, 2005 ^472^ | 69 women with urodynamically proven stress incontinence naive to surgery. | 1 Increased decaffeinated fluids to 3 liters daily (20 cups) or decreased decaffeinated fluids to 750ml (5 cups) daily; 2 Caffeine restriction and increased fluid intake to 2, 2,673ml/day; 3 Caffeine restriction and decreased fluid intake to 872ml/day | Detailed urinary diaries that included information concerning episodes of urgency and leakage. A 24-hour pad test. | No intention to treat. Open label. Allocation concealment unclear.
Cross-over RCT to examine the effect of caffeine restriction and fluid manipulation in the treatment of patients with urodynamic stress incontinence. | Exclusion criteria: Urinary tract infection, hepatic, cardiac or renal disease and diabetes mellitus, use of antidepressants, anticholinergics or diuretics. | | | Baseline data not provided. Sample size justified.
Duration: 4 weeks | Lost of followup: 9 women.
Tomlinson, 1999 ^473^ | 94 women living in own home with self reported urinary incontinence at least 2/week. | 1 Nurse managed behavioral management for continence: caffeine intake 1–2 cups/day, fluid intake 1,800–2,400ml/day before 6:00 P.M., voiding schedule every 4 hours, bowel management.; 2 Recommendation on behavioral changes without special training or monitoring. | Self reported number of episodes and severity of urine incontinence. Pad test to measure grams of lost urine. | No intention to treat. Open label. The article reported outcomes before/after active treatment (one phase of RCT) excluding 44% of randomized women. Baseline data provided for active group only. No justification for sample size.
Quasi-experimental | Exclusion criteria: Urinary tract infection, bladder cancer, retention of urine, need for a caregiver.
RCT to examine the effect of behavioral management for continence on involuntary urine loss in older, rural women living at home. | Loss of followup: 41 women completed the reported self-monitoring phase.
Duration: 4 weeks
Manonai, 2006 ^474^ | 42 healthy perimenopausal and postmenopausal women between 45–70 years old reported at least one type of urinary incontinence. | 1 Self-selected diet with low-fat and low cholesterol foods and soy protein 25g in various forms of soy foods containing more than 50mg/day of isoflavones; 2 Self-selected diet with low fat and low cholesterol foods | Self reported presence of stress and urge urinary incontinence, urgency and frequency of urination (defined by the International Continence Society) scores of symptoms from none (0), mild (1), moderate (2), and severe (3). | No intention to treat.
Cross-over RCT to examine the effect of a soy-rich diet on urogenital symptoms in peri- and postmenopausal women. | Exclusion criteria: Presence or history of sex hormone dependent malignancies, liver or renal disorders, and pathology of urogenital tract. | | | Single blind (physician and cytopathologist).
Duration: Two 12-week diet periods and two 4-week washout periods. | Loss of followup: 5 women withdrew from the study because of their inability to comply with this study and 1 was lost to pelvic examination followup. | | | Allocation concealment unclear. Baseline data provided with no analysis for incontinence rate.
| | | | Sample size not justified.
Brown, 2006 ^475^ | 2,191 women in the Diabetes Prevention Program RCT older than 25 years, body mass index ≥24kg/m2, a fasting plasma glucose level 95–125mg/dl, and a 2-hour post-challenge glucose level 140–199mg/dl. | 1 Intensive lifestyle therapy to lose and maintain at least 7% of initial body weight through a low fat diet and to engage in moderate intensity physical activity for at least 150 minutes/week.; 2 Metformin 850mg twice daily; 3 Placebo twice daily. | Self reported incontinence symptoms by frequency and type using a validated questionnaire | Intention to treat. Double-blind. Randomization was stratified by clinical center.
Placebo controlled multi center RCT to examine the effects of intensive lifestyle intervention or metformin on prevalence of urinary incontinence among overweight pre-diabetic women. | Exclusion criteria: Taking medications that could affect glucose tolerance or serious medical illness. | | | Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified for the primary outcome-diabetes prevention.
Duration: 2.9 years | Loss of followup: 234 (11%) women with missing urinary incontinence data were excluded from the analysis.
Bryant, 2002 ^476^ | 95 consecutive adult patients with urinary symptoms with routine intake of caffeine >100mg every 24 hours. | 1 Education to reduce caffeine intake to <100mg/day plus bladder training.; 2 Bladder training: increasing intervals between voiding; increasing fluid intake to 2 L/day; urinary deferment techniques; ceasing “just in case” voiding | Self reported frequency, urgency and leakage episodes. | No intention to treat. Open label. Allocation concealment unclear.
RCT to examine the effects of caffeine restriction on urinary incontinence symptoms | Exclusion criteria: Cognitive impairment, pregnancy, urinary tract infection. | | | Baseline data confirmed the adequacy of randomization. Sample size not justified.
Duration: 4 weeks | Lost of followup: 21%, 14 subjects failed to return for followup, 4 had anxiety or family problems, 2 were treated, 1 had intercurrent illness.

Table F76 Effects of weight reduction on improvement in urinary continence in females

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Subak, 2005 ^470^ | Weight reduction intervention | Delayed weight reduction intervention | Stress incontinent episodes/week, % improved | 22 | 0 | 92.0 | 0.1 | 45.0 (2.9; 701.9) | 1 (1; 530) | 919 (2; 701)E
N = 48 | | | Urge incontinent episodes/week, % improved | 17 | 3 | 70.0 | 11.0 | 5.7 (1.9; 16.8) | 2 (1; 10) | 590 (100; 1,742)E
| | | Total incontinent episodes/week, % improved | 14 | 4 | 60.0 | 15.0 | 3.5 (1.3; 9.1) | 2 (1; 19) | 450 (52; 1,216)E

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F77 Effect of dietary intervention on urinary incontinence in females (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Baseline (95% CI)
Sample
Manonai, 2006 ^474^ | Self-selected diet with low fat and low-cholesterol foods and soy protein 25g in various forms of soy foods containing more than 50mg/day of isoflavones. | Self-selected diet with low fat and low cholesterol foods | % of women reporting urge incontinence and mean scores after treatments | 0.2 0.5 | 0.3 ± 0.5 | -0.1 (-0.6; 0.3) | -49.5 (-234.4; 135.5)
N = 42 | | | % of women reporting stress incontinence and mean scores after treatments | 0.7 ± 0.7 | 0.7 ± 0.7 | 0.0 (-0.5; 0.5) | 0.0 (-64.2; 64.2)
| | | % of women reporting urgency and mean scores after treatments | 0.6 ± 0.7 | 0.6 ± 0.7 | 0.0 (-0.5; 0.5) | 0.0 (-72.2; 72.2)
| | | % of women reporting frequency and mean scores after treatments | 0.6 ± 0.8 | 0.6 ± 0.7 | 0.0 (-0.5; 0.5) | 0.0 (-75.7; 75.7)
Dowd, 1996 ^471^ | Decrease daily fluid intake by 300cc | Increase daily fluid intake by 500cc | Weekly episodes of urinary incontinence | 0.1 | 0.6
N = 58
Swithinbank, 2005 ^472^ | Caffeine restriction and decreased fluid intake to 872ml/day | Caffeine restriction and increased fluid intake to 2,673 ml/day | Voiding frequency | 6.3 ± 0.4 | 8.3 ± 1.3 | -2.1 (-2.6; -1.5) | -25.1 (-31.7; -18.4)
N = 48 | | Caffeine restriction and increased fluid intake to, 2,673 ml/day | Number of daily wetting episodes | 0.5 ± 0.8 | 0.7 ± 1.2 | -0.2 (-0.6; 0.2) | -28.8 (-92.4; 34.7)
| Increased decaffeinated fluids to 3 liters daily (20 cups) or decreased caffeinated fluids to 750ml/day (5 cups) | Baseline caffeine intake | Voiding frequency | 7.0 ± 1.0 | 7.2 ± 0.6 | -0.3 (-0.7; 0.2) | -3.5 (-9.7; 2.7)
| | Baseline caffeine intake | Number of daily wetting episodes | 0.8 ± 0.6 | 1.6 ± 0.6 | -1.4 (-1.9; -0.9) | -86.9 (-117.9; -55.9)
| Caffeine restriction and decreased fluid intake to 872ml/day | Caffeine restriction and increased fluid intake to 2,673ml/day | 24 hour pad weight increase (gm) | 6.9 ± 3.5 | 7.9 ± 5.9 | -0.2 (-0.7; 0.2) | -2.6 (-8.2; 3.0)
| Increased decaffeinated fluids to 3 liters daily (20 cups) or decreased caffeinated fluids to 750ml/day (5 cups) | Baseline caffeine intake | 24 hour pad weight increase, gm | 7.1 ± 2.5 | 7.6 ± 5.4 | -0.1 (-0.6; 0.3) | -1.6 (-7.4; 4.3)

Bold- significant differences in outcomes at 95%confidence level

Table F78 Effects of diet and weight management on urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Manonai, 2006 ^474^ | Self-selected diet with low fat and low cholesterol foods and soy protein 25g in various forms of soy foods containing more than 50mg/day of isoflavones | Self selected diet with low fat and low cholesterol foods | % of women reporting frequency and mean scores after treatment | 18 | 16 | 50.0 | 44.4 | 1.1 (0.7; 1.8)
N = 42 | | | % of women reporting stress incontinence and mean scores after treatment | 18 | 0 | 51.1 | 0.1 | 37.0 (2.3; 591.5) | 2 (2; 761) | 510 (1; 591)E
| | | % of women reporting urge incontinence and mean scores after treatment | 6 | 8 | 16.7 | 22.2 | 0.8 (0.3; 1.9)
| | | % of women reporting urgency and mean scores after treatment | 21 | 18 | 58.3 | 50.0 | 1.2 (0.8; 1.8)
Brown, 2006 ^475^ | Intensive lifestyle therapy to lose and maintain at least 7% of initial body weight through a low fat diet and to engage in moderate-intensity physical activity for at least 150 minutes each week | Placebo twice daily | Prevalence of urge incontinence after treatment | 156 | 169 | 23.7 | 25.6 | 0.9 (0.8; 1.1)
N = 1,957 | Metformin 850mg twice daily | Placebo twice daily | Prevalence of stress incontinence after treatment | 206 | 242 | 31.3 | 36.7 | 0.9 (0.7; 1.0)
| | | Prevalence of stress incontinence after treatment | 252 | 242 | 39.7 | 36.7 | 1.1 (0.9; 1.2)
| | | Prevalence of urge incontinence after treatment | 182 | 169 | 28.7 | 25.6 | 1.1 (0.9; 1.3)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F79 Effects of dietary and other lifestyle modifications on perceived urinary incontinence in males and females from the community (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95%CI)
Sample
Bryant, 2002 ^476^ | Education to reduce caffeine intake to <100mg/day plus bladder training | Bladder training | Number of voids/24 hours | 6.8 ± 2.0 | 7.9 ± 2.6 | -0.5 (-0.9; -0.1) | -6.0 (-11.2; -0.8)
N = 95 | | | Occasions of urgency/24 hours | 1.6 ± 1.9 | 3.2 ± 2.8 | -0.7 (-1.1; -0.3) | -20.9 (-33.9; -8.0)
95% female | | | Occasions of leakage/24 hours | 1.2 ± 1.9 | 1.4 ± 1.7 | -0.1 (-0.5; 0.3) | -7.9 (-36.7; 20.8)

Bold- significant differences in outcomes at 95% confidence level

Table F80 Effects of behavioral interventions on female urinary incontinence related to pregnancy and birth

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Chiarelli, 2002 ^477^ | 720 women 48 hours after forceps or ventouse deliveries or their babies with a birth weight of 4,000g or more. | 1 Training in pelvic floor exercises and incorporated strategies to improve adherence.; 2 Usual postpartum care | Self reported in bladder diary and during phone survey “occasionally,” “often,” or “always” incontinence symptoms: | Intention to treat. Single blind (physiotherapist). Allocation concealment adequate. Results adjusted to baseline differences. Sample size justified.
RCT to examine the effectiveness of physiotherapist delivered intervention to prevent urinary incontinence among women three months after giving birth. | Lost of followup: 6% | | - leaked even small amounts of urine when coughing, sneezing, laughing, or lifting; - gone to the toilet urgently for fear of leak; - leaked even small amounts before using the toilet; - leaked even small amounts on way to the toilet or immediately as needed
Duration: 3 months
Reilly, 2003 ^478^ | 268 primigravidae women in antenatal clinic at ~20 weeks of gestation with bladder neck mobility, on standardized valsalva, of 5mm or more linear movement. | 1 Supervised by physiotherapist pelvic floor exercises 1/month before delivery: 3 repetitions of 8 contractions each held for 6 seconds to 2 minutes, rest repeated 2/day. At 34 weeks of gestation the number of contractions per repetition was increased to 12.; 2 Verbal advice on pelvic floor exercises from their midwives antenatally | Self reported postpartum stress incontinence. Volume of leakage using one-hour International Continence Society pad test. Pelvic floor muscle strength by perineometry | Intention to treat. Single blind (observers to assess outcomes) Simple randomization with pseudo-random numbers generated by computer. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of supervised pelvic floor exercises antenatally on incidence of postpartum stress incontinence in at-risk primigravidae women. | Exclusion criteria: Urge incontinence.
Duration: 5 months | Loss of followup: 101 due to unwilling to travel to the hospital dislike of perineometry and ultrasound.
Sampselle,1998 ^479^ | 72 primigravidas at 20 weeks of gestation, 18 years or older with negative history of genitourinary pathology, permanent residents in the area, able to read and understand English. | 1 Standardized instruction in pelvic muscle exercise; 2 Routine care with no systematic pelvic muscle exercise instruction | Self reported stress urinary incontinence scores by severity from 0 - no leakage to 3 - soaking. Pelvic muscle strength measured with a new speculum—maximum voluntary contraction force of pelvic muscle | Intention to treat. Single blind (observers to assess outcomes). Simple randomization generated by computer. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effect of pelvic muscle exercise on postpartum symptoms of stress urinary incontinence in primigravidas during pregnancy and postpartum. | Loss of followup: 8 not willing to participate, 6 moved from the area, 5 conceived the second child during 12 months after the first birth, 7 provided incomplete incontinence information.
Duration: 12 months
Chiarelli, 2004 ^480^ followup to Chiarelli, 2002 ^477^ | 720 women 48 hours after forceps or ventouse deliveries or their babies with a birth weight of 4,000g or more. | 1 Training in pelvic floor exercises and incorporated strategies to improve adherence.; 2 Usual postpartum care | Self reported in bladder diary and during phone survey “occasionally,” “often,” or “always” incontinence symptoms: | Intention to treat. Single blind (physiotherapist). Allocation concealment adequate. Results adjusted to baseline differences. Sample size justified.
RCT to examine the effects of physiotherapist-delivered promotion of pelvic floor exercise frequency on continence status for women at 12 months postpartum | Loss of followup: 13.2% in intervention and 14.3% in the control groups. | | - leaked even small amounts of urine when coughing, sneezing, laughing, or lifting; - gone to the toilet urgently for fear of leak; - leaked even small amounts before using the toilet; - leaked even small amounts on way to the toilet or immediately as needed.
Duration: 12 months
Meyer, 2001 ^481^ | 107 white nulliparous women | 1 12 sessions of pelvic floor exercises with 20 minutes of biofeedback and 15 minutes of electrostimulation with an electrode placed in the lower third of the vagina.; 2 No training | Self reported urinary incontinence using questionnaire, perineosonography, urethral pressure profiles, and intravaginal and intra-anal pressure recordings during pelvic floor contraction. | Intention to treat not stated. Open label. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effect of pelvic floor education after vaginal delivery on pelvic floor characteristics in nulliparous women. | Exclusion criteria: Pregnancy complications (twin gestation, diabetes, or preterm labor, hemorrhage from low-lying placenta), women with beginning labor, history of urinary infections.
Duration: 10 months | Loss of followup- not reported.
Labrecque, 2000 ^482^ | Pregnant women with (n = 493) and without (n = 1,034) a previous vaginal birth. | 1 Self administered perineal massage daily from the 34th or 35th week of pregnancy until delivery introducing 1 or 2 fingers 3 to 4cm deep into the vagina and applying and maintaining pressure.; 2 Usual obstetric care. | Self reported urinary and incontinence as ever lost urine involuntarily (accidentally), when coughing, sneezing, laughing, or running. | Intention to treat. Single-blind. Central randomization balanced in blocks of 4 or 6 stratified by history of previous vaginal birth, specialty of the attending physician and hospital. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of perineal massage performed during pregnancy on perineal symptoms after delivery. | Exclusion criteria: High risk of cesarean delivery, including previous cesarean delivery for cephalopelvic disproportion; multiple gestation; placenta previa; severe fetal growth restriction; breech presentation; preeclampsia; nonparticipating physicians; outbreak of genital herpes during the current pregnancy, inability to speak French or English, inability to understand the instructions, and already doing the massage. | | Response choices: never, less than once per week, 1 to 6 times a week, once a day, and more than once a day.
Duration of followup: 3 months | Loss of followup: 0.3%
Glazener, 2001 ^483^ | 747 women with urinary incontinence (defined as any involuntary loss of urine) 3 months postnatally, living within a 50km radius and who delivered in these units during a 12 month recruitment period. | 1 Assessment by nurses of urinary incontinence with conservative advice on pelvic floor exercises (of 8–10 sessions each day of fast and slow contractions with the aim of 80–100 contractions daily) at five, seven, and nine months after delivery supplemented with bladder training if appropriate at seven and nine months.; 2 The control group did not receive any visits from research nurses but received peripartum preparation, which sometimes included pelvic floor exercises, and could seek medical advice | Self reported persistence of any urinary incontinence; severe incontinence - at least once a week; type of incontinence, stress - during cough, laugh, sneeze, run, jump, or play sport; urge - feel an urgent desire to pass water and are unable to reach the toilet in time; mixed—combination of stress and urge. | Intention to treat. Single blind. Computer generated randomization stratified by parity (4 versus fewer), method of delivery (caesarean versus other), and frequency of incontinence (at least once a week versus less). Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effect of nurse assessment with reinforcement of pelvic floor muscle training exercises and bladder training among women with persistent postnatal incontinence | Exclusion criteria: mothers of stillborn or died neonates.
Duration: 12 months | Loss of followup: 25% in active and 35% in the control group.
Glazener, 2005 ^484^ | 747 women with urinary incontinence (defined as any involuntary loss of urine) 3 months postnatally, living within a 50km radius and who delivered in these units during a 12 month recruitment period. | 1 Assessment by nurses of urinary incontinence with conservative advice on pelvic floor exercises (of 8–10 sessions each day of fast and slow contractions with the aim of 80–100 contractions daily) at five, seven, and nine months after delivery supplemented with bladder training if appropriate at seven and nine months.; 2 The control group did not receive any visits from research nurses but received peripartum preparation, which sometimes included pelvic floor exercises, and could seek medical advice | Self-reported 6 years after intervention persistence of any urinary incontinence; severe incontinence - at least once a week; type of incontinence—stress during cough, laugh, sneeze, run, jump, or play sport; urge— feel an urgent desire to pass water and are unable to reach the toilet in time; mixed—combination of stress and urge. | Intention to treat. Single blind. Computer generated randomization stratified by parity (4 versus fewer), method of delivery (caesarean versus other), and frequency of incontinence (at least once a week versus less). Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Adherence to the intervention was the same in active and control group 6 years at followup. Sample size justified.
Glazener, 2001 ^483^ | Exclusion criteria: Mothers of stillborn or died neonates.
RCT to examine the effect of nurse assessment with reinforcement of pelvic floor muscle training exercises and bladder training among women with persistent postnatal incontinence | Loss of followup: 29% in active and 31% in the control group.
Sleep,1987 ^485^ | 1,800 women 24 hours after vaginal delivery. | 1 Standard care: initial instruction on pelvic floor exercise and advice to repeat as often as possible.; 2 Intensive exercise care: initial instruction on pelvic floor exercise, extra session of exercise daily, visits and phone calls by community midwives, reminders, feedback to self measure squeeze pressure, and voiding diary. | Self reported urinary incontinence and frequency of wet episodes/day | Intention to treat. Open label. Randomization schedule not reported. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of pelvic floor exercise on urinary incontinence in postnatal care. | Exclusion criteria: Mothers of stillborn or ill babies.
Duration: 3 months postpartum. | Loss of followup: 10.6%
Mørkved, 2003 ^486^ | 301 healthy nulliparous women ≥18 years, with a single live fetus at routine ultrasound scan. | 1 Training in intensive pelvic floor muscle and general exercises with physiotherapist for 60 minutes/week. Exercise at home twice a day in a preferred position for 12 weeks (between weeks 20 and 36 of pregnancy). Near maximal contractions of 6–8 seconds for 3–4 fast contractions and 6 second resting.; 2 Control group: customary information given by midwife or general practitioner | Self-reported symptoms of urinary incontinence: involuntary leakage >1/week during the last month. Pelvic floor muscle strength (vaginal squeeze pressure [cm/H2O]) measured by a vaginal balloon connected to a pressure transducer | Intention to treat. Single-blind. Randomization in blocks of 32 maximum. Allocation concealment not adequate. Baseline data confirmed the adequacy of randomization. Sample size justified.
RCT to examine the effects of intensive pelvic floor muscle training during pregnancy on prevention of UI. | Exclusion criteria: pregnancy complications, high risk for preterm labor, pain during pelvic floor muscle contractions, ongoing urinary tract infection, diseases that could interfere with participation, residency too far from Trondheim to attend weekly training.
Duration of intervention: 12 weeks. | Loss of follow up:4%
Duration of follow up: 36 weeks of pregnancy and 3 months after childbirth

Table F81 Effects of conservative management on female urinary incontinence related to pregnancy and birth (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Glazener, 2001 ^483^ | Assessment by nurses of urinary incontinence with conservative advice on pelvic floor exercises supplemented with bladder training. | Usual peripartum preparation | Any pad use | 41 | 55 | 14.9 | 22.4 | 0.8 (0.5; 1.1)
N = 747 | | | Any incontinence at 12 months postpartum in women with baseline stress incontinence | 91 | 87 | 24.5 | 23.1 | 1.1 (0.8; 1.4)
| | | Severe incontinence (at least once a week) at 12 months postpartum | 55 | 78 | 14.8 | 20.7 | 0.7 (0.5; 1.0)
| | | Severe incontinence in women with high initial severity (>1/week) | 43 | 65 | 11.6 | 17.3 | 0.7 (0.5; 1.0)
| | | Severe incontinence in women with stress incontinence initially | 29 | 37 | 7.8 | 9.8 | 0.8 (0.5; 1.3)
| | | Urinary incontinence (any) | 167 | 169 | 59.9 | 69.0 | 1.0 (0.9; 1.2)
| | | Urinary incontinence (severe) | 55 | 78 | 19.7 | 31.8 | 0.7 (0.5; 1.0)
Glazener, 2005 ^484^ | Assessment by nurses of urinary incontinence with conservative advice on pelvic floor exercises supplemented with bladder training | Usual peripartum preparation | Self reported presence of any urinary incontinence 6 years after randomization | 201 | 201 | 76.0 | 79.0 | 1.0 (0.9; 1.2)
N = 747 | | | Urinary incontinence at 6 years after index delivery in women we severe (>1 week) initial incontinence | 122 | 102 | 80.0 | 80.0 | 1.2 (1.0; 1.5)
| | | Urinary incontinence at 6 years after index delivery in women with initial stress incontinence | 111 | 97 | 75.0 | 77.0 | 1.2 (0.9; 1.5)
| | | Urinary incontinence at 6 years after index delivery in women with severe initial incontinence (>1/week) | 122 | 102 | 80.0 | 80.0 | 1.2 (1.0; 1.5)
| | | Using pads | 72 | 59 | 28.0 | 24.0 | 1.2 (0.9; 1.7)

Table F82 Effects of conservative management on female urinary incontinence related to pregnancy and birth (self reported severity and impact on life)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Glazener, 2001 ^483^ | Assessment by nurses of urinary incontinence with conservative advice on pelvic floor exercises supplemented with bladder training | Usual peripartum preparation | Mean No of pad changes | 0.2 ± 0.0 | 0.3 ± 0.1 | -2.9 (-3.1; -2.7) | -864.1 (-925.0; -803.2)
N = 747 | | | Mean overall rating of severity (0=no problem at all to 10=can't think of anything worse) | 2.8 ± 0.2 | 3.6 ± 0.3 | -3.1 (-3.3; -2.9) | -87.1 (-93.0; -81.1)
100% female

Bold- significant differences in outcomes at 95% confidence level

Table F83 Effects of behavioral interventions on female urinary incontinence related to pregnancy and births (events)

Author | Active Treatment | Control Treatment | Outcomes | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Labrecque, 2000 ^482^ | Self administered perineal massage daily from the 34th or 35th week of pregnancy until delivery introducing 1 or 2 fingers 3 to 4cm deep into the vagina and applying and maintaining pressure | Usual obstetric care | Urinary continence in women with no previous vaginal birth | 381 | 367 | 73.5 | 71.3 | 1.0
N = 1,034 | | | | | | | | (1.0; 1.1)
| | | Urinary continence in women with previous vaginal birth | 163 | 151 | 66.3 | 61.1 | 1.1
| | | | | | | | (0.9; 1.2)
Labrecque, 2000 ^482^ | Self administered perineal massage daily from the 34th or 35th week of pregnancy until delivery introducing 1 or 2 fingers 3 to 4cm deep into the vagina and applying and maintaining pressure | Usual obstetric care | Urinary incontinence >1/day in women with previous vaginal birth | 9 | 8 | 3.7 | 3.2 | 1.1
N = 493 | | | | | | | | (0.4; 2.9)
Labrecque, 2000 ^482^ | Self administered perineal massage daily from the 34th or 35th week of pregnancy until delivery introducing 1 or 2 fingers 3 to 4cm deep into the vagina and applying and maintaining pressure | Usual obstetric care | Urinary incontinence >1/day in women with no previous vaginal birth | 13 | 12 | 2.5 | 2.4 | 1.1
N = 1,034 | | | | | | | | (0.5; 2.3)
Meyer, 2001 ^481^ | 12 sessions of pelvic floor exercises with 20 minutes of biofeedback and 15 minutes of electro stimulation | Usual care | % recovering normal pelvic floor contraction | 21 | 18 | 41.0 | 33.0 | 1.3
N = 107 | | | | | | | | (0.8; 2.1)
Chiarelli, 2002 ^477^ | Training in pelvic floor exercises and incorporated strategies to improve adherence | Usual postpartum care | Prevalence of self reported urinary incontinence | 115 | 134 | 31.0 | 38.4 | 0.8
N = 720 | | | | | | | | (0.7; 1.0)
| | | % of self reported severe mixed incontinence | 37 | 59 | 10.1 | 16.8 | 0.6 | 15 (10; 46) | 67 (22; 100)A
| | | | | | | | (0.4; 0.9)
Reilly, 2002 ^478^ | Supervised by physiotherapist pelvic floor exercises 1 month before delivery | Verbal advice on pelvic floor exercises | Self-reported postpartum stress incontinence | 23 | 36 | 19.2 | 32.7 | 0.6 | 7 (5; 40) | 135 (25; 205)A
N = 268 | | | | | | | | (0.4; 0.9)
| | | Positive pad test (+ v >1g) | 7 | 8 | 9.5 | 10.8 | 0.8
| | | | | | | | (0.3; 2.1)
Sampselle, 1998 ^479^ | Standardized instruction in pelvic muscle exercise | Routine care with no systematic pelvic muscle exercise instruction | Odds ratio of improved maximum voluntary contraction force of pelvic muscle 1 year after vaginal birth | | | | | 1.0
N = 72 | | | | | | | | (1.0; 1.0)
| | Routine care with no systematic pelvic muscle exercise instruction | Odds ratio of stress incontinence symptoms 1 year after vaginal and cesarean birth | | | | | 1.0
| | | | | | | | (1.0; 1.0)
| | | Odds ratio of stress incontinence symptoms 1 year after vaginal birth | | | | | 1.0
| | | | | | | | (1.0; 1.0)
Chiarelli, 2004 ^480^ | Training in pelvic floor exercises and incorporated strategies to improve adherence | Usual postpartum care | Self-reported incontinence | 101 | 100 | 34.4 | 36.4 | 0.9
N = 720 | | | | | | | | (0.8; 1.2)
Sleep, 1987 ^485^ | Intensive exercise care: initial instruction on pelvic floor exercise, extra session of exercise daily, visits and phone calls by community midwives, reminders, feedback to self measure squeeze pressure, and voiding diary | Standard care: initial instruction on pelvic floor exercise and advice to repeat as often as possible | Cured (no recorded urinary incontinence) | 21 | 22 | 2.3 | 2.4 | 1.0
N = 1,800 | | | | | | | | (0.5; 1.7)
| | | Self reported urinary incontinence > 3times/day | 9 | 9 | 1.0 | 1.0 | 1.0
| | | | | | | | (0.4; 2.5)
| | | Self reported urinary incontinence: sometimes wearing of pads | 29 | 33 | 3.2 | 3.7 | 0.9
| | | | | | | | (0.5; 1.4)
Mørkved, 2003 ^486^ | Intensive pelvic floor muscle training and general exercises | Customary information given by midwife or general practitioner | Self-reported urinary incontinence at 36 wk of pregnancy | 48 | 74 | 32.43 | 48.37 | 0.67 | 6 (4; 19) | 4 (1.9; 159)A
N = 301 | | | | | | | | (0.50;0.89)
| Intensive pelvic floor muscle training and general exercises | Customary information given by midwife or general practitioner | Self-reported urinary incontinence at 3 months after delivery | 29 | 49 | 19.59 | 32.03 | 0.61 | 8 (5; 36) | 124 (28; 189)A
| | | | | | | | (0.41; 0.91)
| Intensive pelvic floor muscle training and general exercises | Customary information given by midwife or general practitioner | Self-reported urinary incontinence at 36 wk of pregnancy in Continent before pregnancy | 29 | 52 | 19.59 | 33.99 | 0.58 | 7 (5; 20) | 144 (49; 208)A
| | | | | | | | (0.39; 0.85)
| Intensive pelvic floor muscle training and general exercises | Customary information given by midwife or general practitioner | Self-reported urinary incontinence at 36 wk of pregnancy in Continent before and at 20 wk | 13 | 30 | 8.78 | 19.61 | 0.45 | 9 (7; 29) | 108 (34; 148)A
| | | | | | | | (0.24; 0.82)
| Intensive pelvic floor muscle training and general exercises | Customary information given by midwife or general practitioner | Self-reported urinary incontinence at 3 months after delivery in Continent before pregnancy | 14 | 28 | 9.46 | 18.30 | 0.52 | 11 (8; 95) | 88 (11; 131)A
| | | | | | | | (0.28; 0.94)
| Intensive pelvic floor muscle training and general exercises | Customary information given by midwife or general practitioner | Self-reported urinary incontinence at 3 months after delivery in Continent before and at 20 wk | 9 | 13 | 6.08 | 8.50 | 0.72
| | | | | | | | (0.32; 1.62)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E- excessive events

Table F84 Effects of behavioral intervention on urinary incontinence related to pregnancy and birth (urodynamic outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI)
Sample
Reilly, 2002 ^478^ | Supervised by physiotherapist pelvic floor exercises once per month before delivery | Verbal advice on pelvic floor exercises | Change in bladder neck mobility, mm | -0.2 ± 0.4 | -0.1 ± 0.5 | -0.2 ( -0.4; 0.1)
N = 268 | | | Perineometry (cm/H2O) | 11.5 ± 7.9 | 10.5 ± 5.5 | 0.1 (-0.1; 0.4)
Meyer, 2001 ^481^ | 12 sessions of pelvic floor exercises with 20 minutes of biofeedback and 15 minutes of electro stimulation | Usual care | Bladder neck position, standing (mm) | 27.0 ± 4.0 | 27.0 ± 5.0 | 0.0 (-0.4; 0.4)
N = 107 | | | Bladder neck mobility, supine (mm) | 14.0 ± 5.0 | 15.0 ± 6.0 | -0.2 (-0.6; 0.2)
| | | Functional urethral length (mm) | 30.0 ± 6.0 | 31.0 ± 7.0 | -0.2 (-0.5; 0.2)
| | | Area of continence at stress (mm2) | 616.0 ± 299.0 | 588.0 ±328.0 | 0.1 (-0.3; 0.5)
| | | Maximal urethral closure pressure at stress (cm/H2O) | 83.0 ± 23.0 | 89.0 ± 30.0 | -0.2 (-0.6; 0.2)
| | | Pressure transmission ratio values (%) in the central third of the functional urethral length | 81.0 ± 23.0 | 77.0 ± 27.0 | 0.2 (-0.2; 0.5)
| | | Intravaginal pressures (cm/H2O) | 33.0 ± 22.0 | 41.0 ± 27.0 | -0.3 (-0.7; 0.1)
| | | Intra-anal pressures (cm/H2O) | 36.0 ± 20.0 | 43.0 ± 24.0 | -0.3 (-0.7; 0.1)

Table F85 Effects of behavioral interventions on risk and progression of incontinence in community dwelling females

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Diokno, 2004 ^487^ | 359 postmenopausal, continent women (0–5 days of incontinent episodes in the previous year) 55 years and older. | 1 2 hour classroom presentation on behavioral modification program: pelvic floor muscle training, bladder training, and individualized test of knowledge, adherence, and skills to reinforce the technique as needed.; 2 Usual care | Self reported in the standardized Medical Epidemiologic and Social Aspects of Aging (MESA) questionnaire absolute continence: urinary incontinence episodes no more than 5 days in the last 12 months. Voiding frequency and intervoid interval reported in 3-day voiding diary. Displacement and pressure digital scores from test for pelvic floor muscle strength. | Intention to treat not stated. Single blind (nurse examiner). Randomizations in blocks of 16 women to provide balanced recruitment between groups. Allocation concealment adequate. Results adjusted to baseline differences. Sample size not justified.
Duplicate: | At baseline 2 groups reported identical 39% absolute continence and zero UI days. 61% of participants reported 1 to 5 UI episodes in year.
Sampselle, 2005 ^488^ | Exclusion criteria: neurologic diseases, mini-mental scores <24, positive paper towel cough test, grade 4 uterine prolapse.
RCT to examine the effects of behavioral modification program on incidence of urinary incontinence in older women. | Loss of followup: 9% in the control and 14% in active groups did not return communication, relocated or experienced changes in personal health or the health of a family member.
Duration: 1 year.
Dumoulin, 2004 ^489^ | 64 premenopausal women younger than 45 years presenting symptoms of stress urinary incontinence at least once per week 3 months or more after their last delivery. | 1 Pelvic floor rehabilitation: 15 minute electrical stimulation of the pelvic floor muscle; then 25 minute pelvic floor muscle exercise program with biofeedback, which included strengthening and motor relearning exercises and a home exercise 5 days/week.; 2 Pelvic floor rehabilitation plus abdominal training: in addition to PFE 30 minutes of deep abdominal muscle training consisting of isolation, reeducation, and functional retraining of the transversus abdominis; 3 Relaxation massage for the back and extremities by physiotherapist. They were asked not to exercise their pelvic floor muscles at home. | 1 20 minute pad test with standardized bladder volume.; 2 Perceived symptoms and burden of incontinence using a Visual Analog Scale Urogenital Distress Inventory (19-items); Incontinence Impact Questionnaire (26 items) focusing on daily living, social interaction, sex life, and self-perception.; 3 Pelvic floor maximum strength and rapidity of contraction using static pelvic floor muscle dynamometer | Intention to treat not stated. Single blind. Stratified randomization by the results from pad test using a balanced block randomization schedule generated from a table of random numbers. Allocation concealment adequate Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to compare the effectiveness of multimodal supervised physiotherapy programs among women with persistent postnatal stress urinary incontinence. | Exclusion criteria: Current pregnancy, urinary incontinence before pregnancy, previous surgery for stress incontinence, moderate to severe urogenital prolapse, involuntary detrusor contraction on cystometry neurologic or psychiatric disease, or a major medical condition, taking medication that could interfere with their evaluation or treatment, inability to understand French or English instructions.
Duration: 2 months | Loss of followup: 2, plus 2 did not attend the final examination and were excluded from the analysis.
Goode, 2003 ^490^ | 200 ambulatory, nondemented, community-dwelling women ages 40 to 78 years with urinary incontinence (at least 2 stress incontinence episodes per week on the 2-week baseline bladder diary) confirmed during urodynamic testing. | 1 Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries). Anorectal biofeedback (~20 minutes) with 3-balloon probe to measure sphincter pressure and rectal pressure. Pelvic floor muscle exercises:15 repetitions of 2- to 4-second contractions with equal periods of relaxation/day. Bladder diary to use “stress strategies” for prevention of urine leakage; 2 Behavioral training plus pelvic floor electrical stimulation 15 minutes/day; 3 Control: self-administered behavioral training administered with a self-help booklet with suggestions for isolating the pelvic floor muscles, progressive home exercise, self monitoring, and bladder control strategies. | Self reported % reduction in the number of incontinent episodes documented in bladder diaries. Leakage in stress test and bladder capacity during urodynamic examination. | Intention to treat. Open label. Computer-generated stratified by types and severity of incontinence and race randomization with block size of 6. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine whether pelvic floor electrical stimulation increases efficacy of behavioral training for community-dwelling women with stress incontinence | Exclusion criteria: Continual leakage, postvoid residual urine volume >150ml, severe uterine prolapse, congestive heart failure, hemoglobin A_1C_ ≥9, or impaired mental status (Mini-Mental State Examination score <24).
Duration: 8 weeks | Loss of followup: 18.2% in the behavioral group, 11.9% in the pelvic floor electrical stimulation group, and 37.3% in the self-help booklet.
Wyman, 1998 ^491^ | 204 community-dwelling women age 45 years and older diagnosed with genuine stress incontinence, (urine loss at least once per week), with urodynamic evidence of genuine stress incontinence, and mentally intact (Mini-Mental State Examination Score >23). | Structured 12-week program of patient education, self-monitoring of voiding behavior with daily treatment logs, compliance assessment, and positive reinforcement administered by trained registered nurses. | Self-reported in a standardized diary the number of weekly incontinent episodes. Patient perception of improvement and treatment satisfaction. | No intention to treat. Open label. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the efficacy of bladder training, pelvic muscle exercise with biofeedback-assisted instruction, and combination therapy, on urinary incontinence in women. | Exclusion criteria: Reversible causes of urinary incontinence, uncontrolled metabolic conditions, residual urine volume after voiding >100ml, urinary tract infection, genitourinary fistula or indwelling catheterization, and inability to correctly perform a pelvic muscle contraction on digital examination. | 1 Bladder training with schedule voiding interval from 30–60 minutes (baseline diary) to increase by 30 minutes each week.; 2 The pelvic muscle exercise with 5 fast (3 second) contractions and 10 sustained (10 second) contractions with 10-second relaxation periods between contractions twice a day. Sustained contractions were increased by 10 contractions/week so that by the third week a total of 10 fast and 40 sustained contractions were performed daily (total = 50 contractions). Visual and verbal biofeedback to observe pelvic and abdominal muscle pressure during fast, sustained, and preventive contractions recorded with vaginal balloon device and displayed on a strip-chart recorder.; 3 Combination therapy of bladder training and pelvic muscle exercise. | Pad weight test.
Duration: 12-week intervention program, 3 month followup | Loss of followup: 6% withdrew either immediately after randomization or during the intervention visits, 8% failed to keep their followup appointment or to mail in completed instruments at the 3-month followup.
Theofrastous, 2002 ^492^ | 137 community-dwelling women age 45 years and older diagnosed with genuine stress incontinence, (urine loss at least once per week), with urodynamic evidence of genuine stress incontinence, and mentally intact (Mini-Mental State Examination Score >23). | 1 Pelvic floor muscle training: 4 office biofeedback sessions and home exercise with two sets of 5 quick and 10 sustained contractions with 10-second rest periods increased to 5 quick and 20 sustained contractions 2/day for a total of 50 contractions per day. Reinforcement with home audiocassette tapes, 4 weekly 30-minute biofeedback sessions, and regular contact with the research nurses.; 2 Bladder training: initial voiding interval of 30 or 60 minutes increased each week depending on the subject's tolerance of the schedule to 22.5 hours. | Self reported urinary incontinence episodes/week using diaries and vaginal pressure measurements by using balloon manometry. | No intention to treat. Open label. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the efficacy of bladder training and pelvic muscle exercise with biofeedback-assisted instruction on urinary incontinence in women. | Exclusion criteria: Reversible causes of urinary incontinence, uncontrolled metabolic conditions, residual urine volume after voiding >100ml, urinary tract infection, genitourinary fistula or indwelling catheterization, and inability to correctly perform a pelvic muscle contraction on digital examination.
Duration: 12-week intervention program, 3 month followup | Loss of followup: 6% withdrew either immediately after randomization or during the intervention visits, 8% failed to keep their followup appointment or to mail in completed instruments at the 3-month followup.
Alewijnse,2003 ^493^ | 129 community-dwelling women over 17 years old with urinary incontinence, able ability to complete questionnaires in Dutch language. | 1 Bladder training with voiding frequency of ~7 voidings/day and pelvic floor muscle exercise: 10 slow twitch contractions (10–30 seconds) and 10 fast twitch contractions (2–3 seconds), 5 times/day, each contraction being followed by relaxation; correct toileting and drinking behavior (1,500–2,000ml/day); techniques to prevent leakage. Combination of PFME with Health education therapy.; 2 Reminder intervention: information and reminders of PFME therapy and adherence behavior; 3 Reminder and self-help guide with individualized information on coping with urinary incontinence, tips to increase adherence behavior, and relapse prevention strategies to support the self-management process.; 4 Reminder, self-help guide and counseling intervention: addition of counseling by physiotherapists, structural oral feedback, and reinforcement to promote adherence behavior. | Self reported weekly frequency of wet episodes and change in frequency of wet episode. | Intention to treat. Open label. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effectiveness of pelvic muscle floor exercise therapy supplemented with a health education program urinary incontinence among women. | Exclusion criteria: Continence, neurological conditions, venereal disease, viral infections, using medication that may impact incontinence, pregnancy or 3 months after delivery, after surgical treatment for incontinence, and women with physical impairments. Severe prolapse, vaginal atrophy, and urinary tract infection were not exclusion criteria.
Duration: 14–22 weeks of intervention and 1 year followup. | Loss of followup: 20% for different reasons, one died.
Aukee, 2004 ^494^ | 35 women 21–70 years old with urodynamically confirmed stress incontinent (maximal urethral closure pressure >20cm/H2O and cough leak point pressure >90cm/H2O). | 1 Home program with given verbal and written instructions for home practice and advise to practice for 20 minutes/day, 5 times/week.; 2 Pelvic floor training by physiotherapist 5 times/12 weeks: 3–5 second contractions with 10 second intervals in supine and standing position with home biofeedback using a personal EMG-assisted biofeedback device. | Review of hospital records to identify gynecologic surgery during 1 year of followup. Pelvic floor muscle activity while supine (mV). | Intention to treat. Open label. Randomization was performed by a random numbers table, in blocks of four. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effectiveness of pelvic floor training with home biofeedback device among women with tress urinary incontinence | Exclusion criteria: Previous incontinence operations, genital prolapse, inability to understand instructions for home training, pregnancy, severe diseases such as malignancies in the abdominal region, multiple sclerosis and diabetes mellitus requiring insulin.
Duration: 12 weeks intervention, 1 year followup. | Loss of followup: 1 woman at 1 year.
Bergman, 1987 ^495^ | 89 women with a clinically and urodynamically proved diagnosis of genuine stress urinary incontinence after surgery for incontinence (40 revised Pereyra procedure and 49 Burch retropubic urethropexy). | 1 “Bladder training” scheduled clamping and unclamping of the suprapubic Bonnano catheter throughout postoperative period.; 2 “Nonbladder training” continuous bladder drainage with suprapubic Bonnano catheter throughout postoperative period. | Length of postoperative bladder catheterization | No intention to treat. Open label. Randomization using a randomization list. Allocation concealment unclear. Baseline data not reported. Sample size not justified.
RCT to examine the effects of bladder training on urinary incontinence in women after surgery for stress urinary incontinence. | Exclusion criteria: Not reported.
Duration of followup: 3 months | Loss of followup: None
Wang, 2004 ^496^ | 120 women age 16–75 years, symptoms of overactive bladder for more than 6 months, frequency of voiding eight times or more per day, and urge incontinence one time or more per day. | 1 Pelvic floor muscle training with submaximal to maximal PFM contractions for 6 seconds 5 times and 10 fast contractions per session at least 3 times/day.; 2 Biofeedback-assisted pelvic floor muscle training with an intravaginal electromyogram probe to contract or relax PFMs following the visual EMG signals.; 3 Electrical stimulation in the management of overactive bladder with intravaginal electrode at the physiotherapy unit. | Self-reported urge urinary incontinence. The strength of the PFMs using palpation by way of the vagina according to the “PERFECT” scheme to assess the power (P), endurance (E), number of repetitions (R), and number of fast (1-second) contractions (F). The power is graded from 0–5, according to the Oxford grading system. PFM strength - vaginal pressure using a balloon probe connected to a pressure transducer. | No intention to treat. Single blind. Central computer-generated randomization in blocks of 6. Allocation concealment adequate. Baseline data did not confirm adequacy of randomization. Sample size justified.
RCT to examine the efficacy of pelvic floor muscle training, biofeedback-assisted PFMT, and electrical stimulation in the management of overactive bladder. | Exclusion criteria: pregnancy, deafness, neurologic disorders, diabetes mellitus, pacemaker or intrauterine device use, genital prolapse greater than Stage II of the International Continence Society grading system, residual urine >100ml, and urinary tract infection.
Duration: 12 weeks. | Loss of followup: 14.2%
Bo, 2005 ^497^ | 52 women with urodynamic stress urinary incontinence participated in the original RCT. | 1 Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months.; 2 Home exercise groups | Self reported urinary incontinence and severity of lower urinary tract symptoms by the severity index and the International Consultation of Incontinence Questionnaire Urinary Incontinence Short Form | Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
Followup RCT to examine the effects of intensive exercise on stress urinary incontinence. | Exclusion criteria: Response rate 90.4%
Duration of followup: 6 months and 15 years | Loss of followup: 9.6%
Elser, 1999 ^498^ | 204 women 45 years or older, ambulatory, mentally intact with urodynamic genuine stress incontinence or detrusor instability, with or without stress incontinence, experiencing 1–100 episodes of incontinence per week as recorded on the qualifying 7-day urinary diary, capable of performing a pelvic floor muscle contraction as assessed by digital exam. | Patient education, self-monitoring with treatment logs, compliance assessment, and positive reinforcement techniques administered by trained research nurses. | Multi-channel urodynamics outcomes: first sensation to void, maximum cystometric capacity, the difference between MCC and FSV (MCC - FSV), functional urethral length, maximum urethral closure pressure, urethral closure pressure, maximum Kegel urethral closure pressure, Kegel urethral closure pressure, pressure transmission ratio, maximum pressure transmission ratio, and straining urethral axis. | No intention to treat Open label. Stratified by severity of urinary incontinence, urodynamic diagnosis, and treatment site randomization. Allocation concealment not reported. Baseline data did not confirm adequacy of randomization. Sample size justified.
RCT to examine the effects of pelvic floor muscle training, bladder training, or both, on urodynamic parameters in women with urinary incontinence. | Exclusion criteria: Reversible cause of incontinence, uncontrolled metabolic conditions (e.g., diabetes mellitus), postvoid residual of >100ml, persistent urinary tract infection, urinary tract fistula, or indwelling catheterization. | 1 Pelvic floor muscle training with 10 fast (3 second) contractions and 40 sustained (10 second) contractions with 10 second rest periods between contractions performed daily (total 50 contractions) in two or more exercise sets. Visual and verbal biofeedback via a strip-chart recorder of vaginal and abdominal pressures measured by vaginal balloons.; 2 Bladder training.; 3 Pelvic floor muscle training combined with bladder training.
Duration: 12 weeks | Loss of followup: 11.3%
Tibaek, 2005 ^499^ | 26 women 40 and 85 years old with acute ischemic stroke verified by CAT scan lasting >24 hours; stroke symptoms in at least 1 month; normal cognitive function (mini-mental state examination >25); urinary incontinence related to stroke; independent walking abilities indoors >100 meters with/without aids; independence in toilet visits. | 1 Intensive pelvic floor muscle training 1–2 times/day by specialized physiotherapist: group information on incontinence and instruction in self-palpation of PFM, motivation and instruction in home exercises with close to maximum contraction (6 second contraction/6 second rest) and endurance PFM exercise with 30% of maximum contraction as long as possible (maximum 30 second contraction/30 second rest). Group treatment: isolate PFM contraction (6 second contraction/6 second rest); strength exercises (3 second contraction/3 second rest, and 6 second contraction/6 second rest); endurance exercises (maximum 30 second contractions/30 second rest).; 2 Usual care | Self reported in voiding diary time and frequency of voiding, the number of incontinence episodes, and the number of used pads. | No Intention to treat. Single blind. Randomization with a table of random numbers. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effect of pelvic floor muscle training in women with urinary incontinence after ischemic stroke. | Exclusion criteria: Urinary tract infection; symptom of vaginal prolapse; chronic respiratory diseases; psychiatric diseases; other neurological diseases; does not speak Danish.
Duration: 12 weeks | Loss of followup: 8%
Subak, 2002 ^500^ | Women 55 years and older with self reported urinary incontinence, members of health maintenance organization, living independently in the community and functionally capable of independent toileting. | 1 6 weekly 20-minute group instructional sessions on bladder training by nurse educators and followed individualized voiding schedules.; 2 Usual care | The number of incontinent episodes per week recorded in a 7-day urinary diary. | No Intention to treat. Single blind. Computer based randomization. Allocation concealment unclear. Baseline confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of low-intensity behavioral therapy program on urinary incontinence in older women | Exclusion criteria: Uncontrolled diabetes mellitus, urinary tract infection, history of urinary obstruction, overflow, functional incontinence, urinary tract anomalies.
Duration of followup: 6 weeks | Loss of followup: 19.1%
Goode, 2002 ^501^ | 105 ambulatory, non demented, community-dwelling women 55 and older with self-reported urge incontinence at least twice per week for >3 months with urodynamic evidence of bladder dysfunction. | 1 Four sessions (over 8 weeks) of biofeedback-assisted behavioral training by nurse practitioners.; 2 Placebo control condition, usual care | Self reported urinary incontinence and urodynamic outcomes. | No Intention to treat. Single blind. Randomization and allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size not justified.
Placebo-controlled RCT to examine the effect of biofeedback-assisted behavioral training on urinary incontinence in older women. | Exclusion criteria: Continual leakage, postvoid residual urine volume greater than 200ml, uterine prolapse past the introitus, narrow-angle glaucoma, unstable angina pectoralis, congestive heart failure, history of malignant arrhythmias, or impaired mental status.
Duration: 8 weeks | Loss of followup: 46.7%
Lagro-Janssen, 1992 ^502^ | 110 women with self-reported urinary incontinence confirmed with urodynamic as stress or urge. | 1 Pelvic floor exercises alone (stress) or bladder training (urge) or its combination (mixed); 2 Usual care | Self reported urinary incontinence | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of pelvic floor exercises on stress incontinence and bladder training on urge incontinence. | Exclusion criteria: Not reported.
Duration: 3 months | Loss of followup: 3.6%
Fantl, 1991 ^503^ | 131 noninstitutionalized women 55 years and older with clinical and urodynamic urinary incontinence >1 leakage/week; mentally intact (Mini-Mental State Examination score >23), capable of independent toileting. | 1 Bladder training using 6 weekly visits included patient education; voiding schedule to have micturition from every 30–60 minutes to every 2.5–3 hours; and positive reinforcement.; 2 Usual care | Self reported number of urinary incontinence episodes/week and urodynamic outcomes using standard urinary diary. | No intention to treat. Open label Randomization stratified by urodynamic incontinence. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of bladder training on urinary incontinence in older women. | Exclusion criteria: Uncontrolled diabetes, urinary tract infection, urinary obstruction, reversible cause of incontinence, permanent catheterization.
Duration: 6 weeks. | Loss of followup:6.1%
Dougherty, 2002 ^504^ | 218 women 55 years and older, who lived in a private residence in rural area; with involuntary urine loss >2/week of 1g/24 hours or more; without urinary tract infection. | 1 Behavioral management for continence: -Self-monitoring and bladder training to reduce caffeinated beverages to <2 cups/glasses, 1,500 <daily fluid intake <4000cc, no fluid consumption after 6 p.m., daytime voiding interval <4 hours, and treatment of constipation. -Pelvic muscle exercise with biofeedback: 15 repetitions per day increased by 15 repetitions every 3 weeks to 45 contractions/day) three times a week for 12 weeks.; 2 Control group | Severity of urine loss was evaluated by pad test. Self reported episodes of urine loss, micturition frequency, voiding interval. | Intention to treat. Open label minimization. Randomization with minimization to balance by severity, age, bacteriuria ethnicity, and caregiver. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of behavioral management for continence on urinary incontinence in older rural women in their homes. | Exclusion criteria: Bladder cancer or kidney disease, indwelling urinary catheter, residual urine >100cc, needed caregiver.
Duration: 6 months and followup 2 years. | Loss of followup:18%
Burgio, 2002 ^505^ | 222 ambulatory, nondemented, community-dwelling women ages 55 to 92 years with urge incontinence or mixed incontinence >2 times/week for at least 3 months, and with urodynamic evidence of bladder dysfunction (detrusor instability during filling or provocation or maximal cystometric capacity of ≤400ml). | 1 Biofeedback-assisted behavioral training implemented by nurse practitioners. Abdominal pressure and sphincter responses were measured with 3-baloon probe inserted in rectum. Pelvic floor muscle exercise with 10 second contractions/10 second relaxation for 45 minutes/day.; 2 4 visits of behavioral training without biofeedback (verbal feedback based on vaginal palpation). Pelvic floor muscle exercise with 10 second contractions/10 second relaxation for 45 minutes/day.; 3 Self-administered behavioral treatment using a self-help booklet to advise pelvic floor exercise and bladder control. | Self reported number of incontinence episodes documented in bladder diaries | Intention-to-treat. Open label. Randomization stratified by race, type, and severity of incontinence. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of biofeedback as a part of complex behavioral training program for urge incontinence in community-dwelling older women. | Exclusion criteria: Continual leakage, postvoid residual urine volume >150ml, severe uterine prolapse past the vaginal introitus, decompensated congestive heart failure, or impaired mental status (Mini-Mental State Examination score <24).
Duration: 8 weeks | Loss of followup: 5.7%
Wyman, 1997 ^506^ | 131 women 55 years and older, ambulatory, mentally intact, independent residents in the community with urodynamic stress urinary incontinence >1 episode/week. | 1 Bladder training: patient education, progressive scheduled voiding regimen, positive reinforcement.; 2 Usual care | Self reported quality of life measures (Incontinence Impact Questionnaire (IIQ) with 26 items and 4 point scale from 0 - not at all to 3 - greatly. | No Intention to treat, Open label. Randomization stratified by type of incontinence. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of bladder training on quality of life in older women with urinary incontinence. | Exclusion criteria: Metabolic decompensation, urinary tract infection, outlet obstruction, fistula, reversible cause of urinary incontinence, permanent indwelling catheter.
Duration: 6 weeks. | Loss of followup: 6%
Yoon, 2003 ^507^ | 50 parous women 35–55 years old a with urine loss of 1.0g or more on a 30 minute pad test and 14 voids or more during a period of 48 hours before the preliminary evaluation. | 1 Bladder training with increased interval between voluntary voids.; 2 Pelvic muscle exercise (30 contractions for 15 to 20 minutes/day) with immediate and simultaneous visual feedback of pelvic muscles during a 20 minute weekly biofeedback session with electromyography.; 3 Usual care | Self reported voids and incontinence scores (5-Likert scale) and urodynamic outcomes | No intention to treat. Single blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified
RCT to examine the effectiveness of bladder training versus pelvic muscle exercises in the treatment of urinary incontinence in women. | Exclusion criteria: Urinary tract infection tested by urinalysis and urine culture, previous experience of surgery for urinary incontinence, HRT and other medication for urinary incontinence.
Duration: 8 weeks | Loss of followup: 8%
Janssen, 2001 ^508^ | 530 women of all ages (mean 47.8 years) with stress, urge, or mixed incontinence. | 1 Individual pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 11 30-minute sessions.; 2 Group pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 9 2-our sessions. | Objective changes in the severity of urinary incontinence, frequency of urine loss, and frequency of nocturnal urine loss. | Intention to treat. Single blind. Stratified by type, severity and duration of incontinence frequency sampling randomization. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of individual and group physiotherapy for urinary incontinence in women. | Exclusion criteria: Neurological cause of incontinence, a tumor or infection in the pelvis, severe vaginal prolapse.
Duration: 3 months, followup 12 months. | Loss of followup: 22%
Nygaard, 1996 ^509^ | 71 women non pregnant women >21 years old with urinary incontinence. | 1 Pelvic floor muscle exercises with 2 5-minute daily sessions, beginning with contractions for 4–8 seconds in combination with specially designed audiotape with 270 minutes of music and verbal instructions of technique tips, reminders, and exercise cues.; 2 Pelvic floor muscle exercises with 2 5-minute daily sessions, beginning with contractions for 4–8 seconds. | Self reported number of incontinent episodes, documented with a 3-day voiding diary | Intention to treat. Single blind. Randomization with random numbers table, in blocks of 4. Allocation concealment not reported. Baseline data not reported. Outcomes reported by type of incontinence, randomization ignored. Sample size justified.
RCT to examine the effects of pelvic floor muscle exercises in combination with specially designed audiotape on stress, urge, and mixed urinary incontinence in women. | Exclusion criteria: Genital prolapse past the vaginal introitus, parturition within the preceding 6 months, and deafness.
Duration: 3 months | Loss of followup: 23%.
McClurg, 2006 ^510^ | 30 women >18 years with multiple sclerosis stabilized for the previous 3 months. Expanded Disability Status Scale score <7.5 with at least one of the following: any involuntary leakage of urine, voiding frequency >8/24 hours, nocturia, and/or reported voiding dysfunction such as hesitancy, straining, poor stream, and incomplete emptying demonstrated by uro-flowmetry. | 1 Pelvic Floor Training and Advice: education with booklet about normal bladder control, lifestyle interventions (weight reduction, relieving constipation, cessation of smoking, caffeine reduction, fluid management, clothing, reducing emotional stress), bladder training, pelvic floor exercise with individualized contractions/relaxation duration based on assessment of power endurance.; 2 Pelvic Floor Training and Advice and EMG Biofeedback.; 3 Pelvic Floor Training and Advice with EMG Biofeedback and neuromuscular electrical stimulation. Stimulation at clinic (weekly) initially for 5 min 30 minutes .using pulse rate 40Hz, pulse width 250msec, with 5sec on and 10 sec off or 10 Hz, 450msec, 10sec on and 3sec off, at maximum-tolerated intensity | 3-day voiding diary; 24 hr pad-test; Uroflowmetry; Pelvic Floor Muscle Assessment; Incontinence Impact Questionnaire (IIQ); Urogenital Distress Inventory (UDI); King's Health Questionnaire (KHQ), and the Multiple Sclerosis Quality of Life-54 Instrument (MSQoL-54). | Intention to treat. Open label. Computer generated randomization list. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size not justified
RCT to examine the effects of pelvic floor training and advice, electromyography biofeedback, and neuromuscular electrical stimulation on urinary incontinence in patients with multiple sclerosis. | Exclusion criteria: MS relapse necessitating hospitalization 3 months prior to or during the study, symptomatic prolapse, presence of urinary tract infection, current or recent diagnosis of a serious medical condition (other than MS), severe cognitive impairment, contraindications to neuromuscular electrical stimulation.
Duration of treatment: 9 weeks. | Loss of follow up: 6.7%
Duration of follow up: 24 weeks

Table F86 Effects of behavioral interventions on risk and progression of stress urinary incontinence in females

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Laycock, 2001 ^511^ | 101 women 20–64 years old with symptoms of stress urinary incontinence. | 1 Pelvic floor exercise with maximum contraction for 1 second and rest for 4 seconds, 10 minutes/day combined with home pressure biofeedback using intra-vaginal perineometer.; 2 Vaginal cones for 10 minutes/day with individually adjusted size and increasing weight.; 3 Pelvic floor exercise for 10 minutes/day. | Pad use/day, wet episodes/day, Pelvic floor muscles contractility | No intention to treat. Open label. Permuted block randomization in ratio 2:2:1.
RCT to examine the effects of vaginal cones, pressure biofeedback, and pelvic floor exercises on stress urinary incontinence in females. | Exclusion criteria: Moderate or severe urge urinary incontinence, moderate or severe genital prolapse, pregnancy or plans to become pregnant, use of medications that can affect the lower urinary tract, HRT for <3 months, neurological diseases. | | | Allocation concealment not reported. Baseline data not reported. Sample size not justified.
Duration: 3 months. | Loss of followup: 32.7%
Bo, 2000 ^512^ | 59 women with clinically and urodynamically proven genuine stress incontinence .4grams of leakage measured by the pad test. | 1 Pelvic floor muscle exercise with 8–12 maximum contractions in 3 series/day and 45 minutes/week group sessions.; 2 Untreated control group | Self reported urinary incontinence using 7 point satisfaction scale. | No Intention to treat. Open label. Computer generated randomization stratified by degree of leakage. Allocation concealment unclear.
RCT to examine the effects of pelvic floor muscle exercise on female genuine stress incontinence. | Exclusion criteria: Urinary incontinence other than GSI, involuntary detrusor contractions exceeding 10cm/H2O on cystometry, residual urine .50ml, maximal uroflow, 15ml/second, previous surgery for GSI, neurological or psychiatric disease, ongoing urinary tract infections, other diseases that could interfere with participation, use of concomitant treatments during the trial, and inability to understand instructions given in Norwegian. | | Norwegian version of the Quality of Life Scale (QoLS-N) and the Bristol Female Lower Urinary Tract Symptoms (B-FLUTS) questionnaire. | Baseline data confirmed adequacy of randomization. Sample size justified
Duration: 6 months. | Loss of followup: 6.7%.
Bo,1999 ^513^ | 107 women with clinically and urodynamically proved genuine stress incontinence >4g of leakage measured by pad test with standardized bladder volume. | 1 Pelvic floor exercise with 8–12 contractions 3 times/day and in groups with skilled physical therapists 1/week.; 2 The electrical stimulation using vaginal intermittent stimulation with the MS 106 Twin at 50Hz 30 minutes/day.; 3 The vaginal cones of 20, 40, and 70g for 20 minutes/day.; 4 The untreated control group offered the use of a continence guard. | Muscle strength measured by vaginal squeeze pressure 1/month. Pad test with standardized bladder volume. 24 hour pad test. Self reported symptoms of severity. | Intention to treat. Single blind. Computer generated random numbers stratified by baseline leakage. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of pelvic floor exercises, electrical stimulation, vaginal cones, and no treatment on females genuine stress incontinence. | Exclusion criteria: urinary incontinence other than genuine stress incontinence, involuntary detrusor contractions >10cm/H2O on cystometry, abnormal bladder function (residual urine >50ml and maximal uroflow <15ml/second), previous surgery for genuine stress incontinence, neurological or psychiatric disease, ongoing urinary tract infections, other diseases that could interfere with participation, use of concomitant treatments during the trial, and inability to understand instructions given in Norwegian. | | Leakage index. Patients indicated on a 5 point scale (5 always, 4 often, 3 sometimes, 2 seldom, 1 never) the frequency of urinary leakage during sneezing, coughing, laughing, walking, walking downhill, running, jumping, and lifting. The mean was calculated as an index of leakage frequency before and after treatment. Objective cure as <2g leakage on the pad test with standardized bladder volume. Subjective cure as (number of women stating that the condition was “unproblematic” after the treatment).
Duration: 6 months | Loss of followup: 12.3%
Cammu,1998 ^514^ | 60 ambulatory and fit white women with urodynamic urinary stress incontinence, and vaginal capacity permitting the use of a vaginal probe-EMG biofeedback-or cones post-partum period, and had neither a genital prolapse nor any other associated pathology that warranted surgery. Furthermore, these women had no detrusor instability, no outflow obstruction, and no intrinsic urethral sphincter deficiency. | 1 Weekly session of pelvic floor exercises vaginal probe-EMG biofeedback using perineometer; 2 Vaginal weight cones (20, 32, 45, 57, and 70g) for 15 minutes, twice daily. | Self reported urinary incontinence using visual analog scale. Pad test | Intention to treat. Open label. Computerized randomization with random numbers tables. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified
RCT to examine the effects of pelvic floor exercises and vaginal weight cones in the treatment on female genuine stress incontinence. | Loss of followup: Not reported
Duration: 12 weeks
Miller, 1998 ^515^ | 27 women with self reported stress urinary incontinence and demonstrable urine loss during a deep cough with leakage occurring at least weekly and up to 5 times/day. | 1 Immediate intervention group taught intentionally contracting the pelvic floor muscles before and during a cough (Knack); 2 Wait-listed control group | Self report 6-day urination diary, digital test for pelvic muscle strength and self reported symptoms (possible score range: 0–21). | Intention to treat not stated. Single-blind randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of intentionally contracting the pelvic floor muscles before and during a cough on mild and moderate female stress urinary incontinence. | Exclusion criteria: History of systemic neuromuscular disease, previous bladder surgery, active urinary tract infection, leakage that was delayed after coughing and categorized as detrusor instability, leakage that saturated a paper towel and/or pooled on the floor when coughing in the standing posture, inability to demonstrate any voluntary contraction of the pelvic floor muscles despite detailed instruction during the pelvic exam, and significant coexistent pelvic organ prolapse below the hymenal ring. Loss of followup: Not reported
Duration: 1 week
Aksac, 2003 ^516^ | 50 postmenopausal women with female urinary stress incontinence taking HRT. | 1 Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds, 10 times/session, 3 sessions/day) via digital palpation at home; 2 Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds) via biofeedback (vaginal probe in EMG pressure mode) 3 times/ week.; 3 Usual care, hormone replacement therapy | Pad test, perineometry outcomes, digital palpation based Pelvic floor muscle strength, incontinence frequency: 1=urine loss 1/day, 2=urine loss >1/week, 3=urine loss <1/week, 4=urine loss 1/month). Visual analog scale based social activity index: 0=cannot undertake any social activity, 10=does not have any problem. | Intention to treat not stated. Randomization with choosing closed letters (patients had to pick up closed letters). Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of pelvic floor muscle exercises or biofeedback on female urinary stress incontinence. | Exclusion criteria: Not reported.
Duration: 2 months | Loss of followup: Not reported.
Burns, 1993 ^517^ | 135 community-dwelling women older than 55 years with sphincteric incompetence, >3 urine losses/week, urodynamic incontinence, >23 scores in Mini-Mental State exam. | 1 Biofeedback using vaginal EMG probe, contraction for 10 seconds and relaxations for 10 seconds 10 times in each weekly session.; 2 Pelvic muscle exercise with 4 sets of 20 increasing by 10/set until maximum 200 sets/day.; 3 Usual care. | Self reported urinary incontinent episodes, improvement in incontinence. | No Intention to treat. Single-blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified
RCT to examine the effects of biofeedback and pelvic muscle exercise treatment on stress incontinence in older community-dwelling women. | Exclusion criteria: glycosuira, pyuria, residual urine >50cc, Peak urine flow <15cc/second | | Urodynamic outcomes.
Duration: 6 months | Loss of followup: 7%
Sherman, 1997 ^518^ | 39 female active duty soldiers with exercise-induced urinary incontinence (stress or mixed). | 1 Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 5 times/session, 20 minutes twice/day with urethral biofeedback using vaginal EMG probe.; 2 Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 5 times/session 20 minutes twice/day alone. | Self reported urinary incontinence symptoms. | Intention to treat not stated. Open label. Randomization stratified by diagnosis of physical stress incontinence or mixed urge/stress incontinence. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified
RCT to examine the effects of pelvic muscle exercises with urethral biofeedback on exercise-induced urinary incontinence in females soldiers. | Exclusion criteria: not reported. | | Urodynamic outcomes.
Duration: 8 weeks. | Loss of followup: not reported.
Burns,1990 ^519^ | 128 women with stress or mixed urinary incontinence >3/week with Mini-Mental scores >23. | 1 Kegel pelvic floor exercises 4 times/day.; 2 Biofeedback with vaginal EMG probe and visual control.; 3 Usual care. | Self reported urinary symptoms. | No Intention to treat not stated. Single blind. Randomization with permuted blocks of 10. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of pelvic floor exercises or biofeedback on female stress urinary incontinence. | Exclusion criteria: urinary tract infection. | | Electromyographic outcomes
Duration: 8 weeks | Loss of followup: not reported.
Wells, 1991 ^520^ | 157 community-living women, ages 55 to 90 years. | 1 Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds, 90–160 times/day.; 2 Phenylpropanolamine hydrochloride in a dose of 50mg /day, increasing to 50mg 2 times/ day. | Subjective improvement, self recorded frequency of wetting. | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified
RCT to examine the effects of pelvic muscle exercise or pharmacologic treatment of stress urinary incontinence in community-living elderly women. | Exclusion criteria: nursing home residency Loss of followup: 34% in active and 15% in control group.
Duration: 6 months
Aukee, 2002 ^521^ | 30 women with urodynamically tested stress incontinence ages 31 to 69 years without previous incontinence operations and an abdominal leak point pressure >90. | 1 Pelvic floor muscle exercise after verbal and written instructions for home practice of 20 minutes/day 5 times/week and individual EMG-assisted biofeedback device with vaginal probe and verbal control.; 2 Pelvic floor muscle exercise after verbal and written instructions for home practice of 20 minutes/day 5 times/week. | 24 hour pad test, leakage index of 13 types of physical exertions that trigger urinary leakage in women with stress incontinence. | Intention-to-treat. Open label. Randomization with random numbers table with permuted blocks of four. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of electromyography-assisted biofeedback training and pelvic floor muscle training on female stress urinary incontinence. | Exclusion criteria: Genital protrusion beyond the vaginal hymen, an inability to understand instructions for home training, pregnancy, and any severe disease such as malignancy in the abdominal region, multiple sclerosis, and insulin-dependent diabetes.
Duration: 12 weeks. | Loss of followup: 6.7%
Berghmans, 1996 ^522^ | 40 women 18–70 years with mild or moderate stress incontinence (grade 1). | 1 Pelvic floor muscle exercise 12 treatment sessions, 3 times/week with contractions 3 –30 seconds 10–30 times beginning with 4 sets of 10 (5 quick and 5 sustained) and increased by 10 per set until 30 times/set. Biofeedback with EMG vaginal probe and visual control.; 2 Pelvic floor muscle exercise 12 treatment sessions, 3 times/week with contractions 3–30 seconds 10–30 times beginning with 4 sets of 10 (5 quick and 5 sustained) and increased by 10 per set until 30 times/set. | Involuntary urine loss, measured with 48 hours pad test. Self completed urinary symptoms questionnaire as 10-point scale and maximum of 50 points for more serious problem: | Intention to treat Single blind. Computer generated randomization stratified by seriousness of incontinence (grade 1 and 2) and by referral (general practitioner or urologist) with permuted blocks of 4. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of biofeedback and pelvic floor muscle exercise on female genuine stress incontinence. | Exclusion criteria: Use of medicine to counteract functional disabilities of the lower urinary tract, pronounced lesions of the pudendus nerve during clinical neurophysiological examination, positive sediment of urine culture, non-compliance in the diagnostic phase, neurogenic bladder function disability caused by surgery of urological and or gynecological nature, period of 6 weeks after a delivery, other forms of treatment to cure stress incontinence, stress incontinence grade 3 or 4, psychological disorders, irritable vagina, pacemaker, hip prosthesis, pathology such as spina bifida, spinal cord lesion. | | 1 At what level of bladder pressure involuntary loss of urine starts; 2 Degree of wet caused by involuntary loss of urine; 3 Frequency of involuntary loss of urine; 4 Level of limitation of social activities because of incontinence; 5 Emotional state related to involuntary loss of urine
Duration: 12 weeks. | Loss of followup: none
Liebergall-Wischnitzer,2005 ^523^ | 59 women, mainly hospital employees with stress or mixed urinary incontinence with urine loss >1gin pad test. | 1 Paula method of circular muscle training 15–45 minutes/day with training sessions of 45 minutes/week; 2 Pelvic floor muscle exercise 15 minutes with 30 minute lesson session/week. | Self reported incontinence, quality of life (I-QOL), 1-hour pad test, and pelvic floor muscle strength (assessed by perineometer and digital examination). | No intention to treat. Single blind. Computer generated randomization with block of 4 stratified by age. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of circular muscle exercises on female urinary stress incontinence. | Exclusion criteria: Pregnancy, severe cardiac or respiratory diseases, pelvic surgery within 6 months, grade 3 and 4 cystocele, previous pelvic radiation, active mucosal lesion in vagina or perineum.
Duration: 12 weeks. | Loss of followup: 13.3%
Sung, 2000 ^524^ | 90 married women with urinary incontinence. | 1 Functional electrical stimulation-biofeedback for 20 minutes/session with frequency 35Hz–50Hz and contractions of 32 seconds, 2 sessions/week; 2 Intensive pelvic floor muscle exercises; 3 Control usual care | Jackson's Bristol female urinary symptom questionnaire with scores from 1 (not a problem) to 5 - very serious problem). | Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of pelvic floor muscle exercises on female genuine stress incontinence. | Exclusion criteria: not reported. | | Objective changes of pelvic muscle contraction force measured by perineometer.
Duration: 6 weeks | Loss of followup: not reported.
Lagro-Janssen, 1991 ^525^ | 66 women ages 20–65 years with genuine stress incontinence. | 1 Instructions in pelvic floor exercises 5–10 sessions of 10 pelvic muscle contractions for 6 seconds each day.; 2 No therapy | Self reported urinary incontinence and impact of incontinence on life. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of pelvic floor exercise on urinary incontinence in women. | Exclusion criteria: Previously undergone an operation for incontinence; if they suffered from underlying neurological causes for incontinence, from diabetes mellitus or from urinary tract infection; or if there was a temporary cause for their incontinence (for example, pregnancy or bed rest).
Duration: 3 months | Loss of followup: none.
Kim, 2001 ^526^ | 48 women 20–75 years old with stress or mixed urinary incontinence. | 1 Continence efficacy intervention program: common pelvic floor muscle education, audiovisual tape, calendar, counseling, schedule guideline, assessing self-care methods.; 2 Conventional care. | Self reported urinary continence and improvement in symptoms of urinary incontinence graded from 0 to 100. | No Intention to treat. Open label. Randomization by the order of coming to the clinic. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of continence efficacy intervention program on stress urinary incontinence in Japanese women. | Exclusion criteria: Drug or surgery treatment for incontinence.
Duration: 3 months. | Loss of followup: 15.2%
Arvonen, 2001 ^527^ | 37 women ages 25–65 with stress urinary incontinence, understanding of spoken Swedish. | 1 Pelvic floor muscle training program with contractions/relaxations for 5 seconds 10 times twice a day.; 2 Pelvic floor muscle training program with contractions/relaxations for 20/20 seconds 10 times twice a day using weighted vaginal balls 50–100g. | Pad-test with a standardized bladder volume. The strength of the pelvic floor musculature assessed by vaginal palpation graded from 0=no contraction to 5=very strong pressure with a strong lift for 6±7 seconds. | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of pelvic floor muscle training with and without vaginal balls on females stress urinary incontinence. | Exclusion criteria: Pregnancy, cysto/rectocele, prolapse, urinary tract infection, altered vaginal tissue, and medication affecting the functioning of the urinary tract or kidneys.
Duration: 4 months | Loss of followup: 7%
Borello-France, 2006 ^528^ | 44 women 38 to 70 years old, ambulatory, with symptoms of stress urinary incontinence >1/week. | 1 Pelvic floor muscle exercises with EMG biofeedback in the supine position only using maximum 30–60 repetitions of 3–12 second contractions twice daily.; 2 Pelvic floor muscle exercises with EMG biofeedback in both supine and upright positions,1 set (3- and 12-second contractions) in each position with maximum 20 repetitions (2 sets of 10) of the 3–12 second contractions twice daily. | 1-week bladder diary, 1 hour pad test, urodynamic outcomes, quality-of-life (Incontinence Impact Questionnaire ranges from 0–400 with poorer perceived quality of life). | Intention-to-treat. Open label. Block randomization schedule with a random-number table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of exercise position during pelvic-floor muscle exercises on females stress urinary incontinence. | Exclusion criteria: Pregnancy, symptoms of urgency or urge urinary incontinence, prior treatments for stress urinary incontinence (collagen injection, medications affecting bladder tone, pessary, or surgery), practicing pelvic-floor muscle exercises, pacemaker, use of intrauterine device, medical history of pelvic cancer, severe endometriosis, neurologic or metabolic disorders likely to impair bladder or sphincter function.
Duration:12-weeks | Loss of followup: 18%
Mørkved, 2002 ^529^ | 103 women with symptoms of stress incontinence and >2g leakage measured by a pad test with standardized bladder volume. | 1 Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day with a biofeedback apparatus; 2 Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day without biofeedback | Pad test with standardized bladder volume with 300ml of saline. Women wore pre-weighed pads and jumped with legs in subsequent adduction and abduction (jumping jacks/star jumps: 20 repetitions) and coughed three times. | Intention to treat. Single blind. Centralized but no computerized randomization stratified by results of a pad test with standardized bladder volume (20g or less and more than 20g of leakage). Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of individual pelvic floor muscle training with and without biofeedback in women with urodynamic stress incontinence. | Exclusion criteria: involuntary detrusor contractions on cystometry, abnormal bladder function (residual urine >50ml), previous surgery for stress incontinence, neurologic or psychiatric disease, urinary tract infection, other diseases that could interfere with participation, pregnancy, use of concomitant treatments during the trial period, and inability to understand instructions in Norwegian. | | Objective cure ≤2g of leakage.
Duration of treatment and followup: 6 months | Loss of follow up: 8.7% | | Self-report of severity using 5-point scale (unproblematic, minor problem, moderate problem, problematic, very problematic).
| | | Subjective cure - reporting the leakage to be unproblematic after treatment.
| | | The leakage index in 5-point scale (1-never, 5-always) containing 13 types of physical activities known to trigger urinary leakage.
| | | The social activity index with nine social settings and 10cm visual analogue scale (0 - impossible to participate, 10 - no problem to participate).

Table F87 Effects of behavioral interventions on urinary continence in females (events) (tables sorted by rate of urinary continence after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Definition of Cure | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Aksac, 2003 ^516^ | Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds) via biofeedback (vaginal probe in EMG pressure mode) 3 times/week | Usual care | Cure from stress urinary incontinence in pad test | 16 | 0 | 80.0 | 0 | 17.3 | | 799 (0; 261)E
N = 50 | | | | | | | | (1.1; 261.7)
| Pelvic floor muscle exercise (contractions for 10 sec and relaxation for 20 sec, 10 times/session, 3 sessions/day) via digital palpation at home | | Cure from stress urinary incontinence in pad test | 15 | 0 | 75.0 | 0 | 16.2 | | 749 (0; 246)E
| | | | | | | | (1.1; 246.5)
Bo, 2005 ^497^ | Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months | Home exercise groups | Self reported cure from incontinence 6 months followup | 13 | 4 | 60.0 | 17.0 | 4.0 | 2 (1; 11) | 430 (91; 1,620)E
N = 47 | | | | | | | | (1.5; 10.5)
Borello-France, 2006 ^528^ | Pelvic floor muscle exercises with EMG biofeedback in the supine position only using maximum 30–60 repetitions of 3–12 second contractions twice daily. | Pelvic floor muscle exercises with EMG biofeedback in both supine and upright positions, 1 set (3- and 12-second contractions) in each position with maximum 20 repetitions (2 sets of 10) of the 3–12 second contractions twice daily. | Urinary continence (objective cure in urodynamic exam) | 13 | 13 | 59.1 | 59.1 | 1.0 (0.6; 1.6)
N = 44
Mørkved, 2002 ^529^ | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day with a biofeedback apparatus | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day without biofeedback | Objective Cure (<2g of Leakage on the Pad Test) | 28 | 21 | 52.83 | 42.00 | 1.26
N = 103 | | | | | | | | (0.83; 1.90)
100% female | | | Urinary incontinence unproblematic | 19 | 14 | 35.85 | 28.00 | 1.28
Followup: 6 months | | | | | | | | (0.72; 2.27)
Bo, 1999 ^513^ | Pelvic floor exercise with 8–12 contractions 3 times/day and in groups with skilled physical therapists 1/week. | Untreated control group offered the use of a continence guard | Subjective cure as (number of women stating that the condition was “unproblematic” after the treatment) | 14 | 1 | 48.3 | 3.1 | 15.4 | 2 (0; 27) | 452
N = 122 | | | | | | | | (2.2; 110.3) | | (36; 3,415)E
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) and Pelvic floor electrical stimulation | Self-administered behavioral training administered with a self-help booklet | % of women with no leakage in post treatment urodynamic testing | 32 | 25 | 47.2 | 37.5 | 1.3 (0.9; 1.9)
N = 200
Wang, 2004 ^496^ | Electrical stimulation in the management of overactive bladder with intravaginal electrode at the physiotherapy unit | Pelvic floor muscle training | Cured urge incontinence | 17 | 12 | 40.0 | 30.3 | 1.3 (0.7; 2.5)
N = 120
Cammu, 1998 ^514^ | Weekly session of pelvic floor exercises vaginal probe-EMG biofeedback using perineometer. | Vaginal weight cones (20, 32, 45, 57, and 70g) for 15 minutes twice daily | Negative stress test | 12 | 12 | 40.0 | 40.0 | 1.0 (0.5; 1.9)
N = 30
Wang, 2004 ^496^ | Biofeedback-assisted pelvic floor muscle training with an intravaginal electromyogram probe to contract or relax PFMs following the visual EMG signals. | Pelvic floor muscle training | Cured urge incontinence | 15 | 12 | 38.2 | 30.3 | 1.3 (0.7; 2.4)
N = 120
Bo, 1999 ^513^ | Pelvic floor exercise with 8–12 contractions 3 times/day and in groups with skilled physical therapists 1/week. | Untreated control group offered the use of a continence guard | Objective cure as <2g leakage on the pad test with standardized bladder volume | 11 | 2 | 37.9 | 6.3 | 6.1 | 3 (1; 34) | 317
N = 122 | | | | | | | | (1.5; 25.1) | | (29; 1,507)E
Kim, 2001 ^526^ | Continence Efficacy Intervention Program: common pelvic floor muscle education, audiovisual tape, calendar, counseling, schedule guideline, assessing self-care methods. | Conventional care | Self reported cure | 6 | 2 | 37.5 | 11.8 | 3.2
N = 33 | | | | | | | | (0.7; 13.6)
Diokno, 2004 ^487^ | Behavioral modification program: pelvic floor muscle training, bladder training | Usual care | % of absolute continent | 61 | 55 | 37.0 | 28.0 | 1.3 (1.0; 1.8)
N = 359
Elser, 1999 ^498^ | Pelvic floor muscle training with visual and verbal biofeedback | Bladder training | Cured from incontinence (self reported and urodynamic) | 25 | 17 | 36.8 | 25.0 | 1.5 (0.9; 2.5)
N = 204
Alewijnse, 2003 ^493^ | Pelvic floor muscle exercise with reminder and self-help guide | Bladder training and pelvic floor muscle exercise | % cured (100% dry) 1 year after intervention | 17 | 21 | 32.7 | 41.2 | 0.8 (0.5; 1.3)
N = 129
Bo, 2005 ^497^ | Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months | Home exercise groups | Self reported continence 15 years followup | 6 | 4 | 28.6 | 15.4 | 1.9 (0.6; 5.7)
N = 47
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) | Self-administered behavioral training administered with a self-help booklet | % of women with no leakage in post treatment urodynamic testing | 18 | 25 | 27.6 | 37.5 | 0.7 (0.4; 1.2)
N = 200
Wells, 1991 ^520^ | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 90–160 times/day | Phenylpropanolamine hydrochloride in a dose of 50mg/day, increasing to 50mg 2 times/day | Cure from stress urinary incontinence (dry) | 22 | 11 | 27.0 | 14.0 | 1.9 (1.0; 3.6)
N = 157
Wyman, 1998 ^491^ | Combination of bladder training and pelvic muscle exercise | Bladder training | % cured at 3 months followup | 16 | 10 | 27.0 | 16.0 | 1.6 (0.8; 3.3)
N = 204
Arvonen, 2001 ^527^ | Pelvic floor muscle training program with contractions/relaxations for 5 seconds 10 times 2 times/day | Pelvic floor muscle training program with contractions/relaxations for 20/20 seconds 10 times 2 times/day using weighted vaginal balls 50–100g | No Leakage (g) | 5 | 9 | 26.3 | 50.0 | 0.5 (0.2; 1.3)
N = 37
Berghmans, 1996 ^522^ | Pelvic floor muscle exercise with biofeedback with EMG vaginal probe and visual control. | Pelvic floor muscle exercise | Cure from stress urinary incontinence | 5 | 3 | 25.0 | 15.0 | 1.7 (0.5; 6.1)
N = 40
Burns, 1993 ^517^ | Biofeedback using vaginal EMG probe, contraction for 10 seconds and relaxations for 10 seconds 10 times in each weekly session | Usual care. | Cure from stress urinary incontinence | 9 | 1 | 23.0 | 3.0 | 8.8 | 5 (1;201) | 200 (5; 1,951)E
N = 135 | | | | | | | | (1.2; 66.0)
Janssen, 2001 ^508^ | Individual pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 11 30 minute sessions. | Group pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 9 2 hour sessions | % cured (urinary continent) at 9 months | 28 | 57 | 22.0 | 14.0 | 1.6 (1.0; 2.4) | 13 (143; 5) | 80 (7; 191)E
N = 530
Lagro-Janssen, 1991 ^525^ | Instructions in pelvic floor exercises 5–10 sessions of 10 pelvic muscle contractions for 6 seconds each day. | No therapy | Urinary continence | 7 | 1 | 21.2 | 3.0 | 7.0
N = 66 | | | | | | | | (0.9; 53.8)
Wyman, 1998 ^491^ | Pelvic muscle exercise with biofeedback-assisted instruction | Bladder training | % cured at 3 months followup | 13 | 10 | 20.0 | 16.0 | 1.3 (0.6; 2.7)
N = 204
Janssen, 2001 ^508^ | Individual pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 11 30 minute sessions. | Group pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 9 2 hour sessions | % cured (urinary continent) at 3 months | 25 | 53 | 20.0 | 13.0 | 1.5 (1.0; 2.3)
N = 530
Burgio, 2002 ^505^ | 4 visits of behavioral training without biofeedback (verbal feedback based on vaginal palpation). Pelvic floor muscle exercise with 10 second contractions and 10 second relation for 45 minutes/day | Self-administered behavioral treatment using a self-help booklet to advice pelvic floor exercise and bladder control | % cured | 15 | 11 | 20.0 | 15.0 | 1.4 (0.7; 2.8)
N = 222 | Biofeedback-assisted behavioral training implemented by nurse practitioners | Self-administered behavioral treatment using a self-help booklet to advice pelvic floor exercise and bladder control | % cured | 15 | 11 | 20.0 | 15.0 | 1.4 (0.7; 2.8)
Lagro-Janssen, 1992 ^502^ | Pelvic floor exercises alone (stress) or bladder training (urge) or its combination (mixed) | Usual care | Self reported urinary continence cured | 10 | 1 | 18.5 | 1.8 | 10.4 | 6 (1; 150) | 167
N = 106 | | | | | | | | (1.4; 78.3) | | (7; 1,380)E
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) | Self-administered behavioral training administered with a self-help booklet | % of patients with 100% reduction in weekly incontinence episodes cured | 11 | 10 | 17.0 | 15.0 | 1.1 (0.5; 2.5)
N = 200
Burns, 1993 ^517^ | Pelvic muscle exercise with 4 sets of 20 increasing by 10/set until maximum 200 sets/day | Usual care | Cure from stress urinary incontinence | 7 | 1 | 16.0 | 3.0 | 6.3
N = 135 | | | | | | | | (0.8; 49.3)
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) and pelvic floor electrical stimulation | Self-administered behavioral training administered with a self-help booklet | % of patients with 100% reduction in weekly incontinence episodes cured | 10 | 10 | 15.0 | 15.0 | 1.0 (0.4; 2.2)
N = 200
Elser, 1999 ^498^ | Pelvic floor muscle training combined with bladder training | Bladder training | Cured from incontinence (self reported and urodynamic) | 10 | 17 | 14.7 | 25.0 | 0.6 (0.3; 1.2)
N = 204
Bo, 1999 ^513^ | The vaginal cones of 20, 40, and 70g for 20 minutes/day. | Untreated control group offered the use of a continence guard | Objective cure as <2g leakage on the pad test with standardized bladder volume | 4 | 2 | 13.8 | 6.3 | 2.2
N = 122 | | | | | | | | (0.4; 11.2)
Fantl, 1991 ^503^ | Bladder training using 6 weekly visits included patient education; voiding schedule to have micturition from every 30–60 minutes to every 2.5–3 hours; and positive reinforcement. | Usual care | Self reported urinary continence (cured) | 8 | 2 | 12.0 | 3.0 | 4.1
N = 131 | | | | | | | | (0.9; 18.4)
Bo, 1999 ^513^ | The electrical stimulation using vaginal intermittent stimulation with the MS 106 Twin at 50Hz 30 minutes/day. | Untreated control group offered the use of a continence guard | Subjective cure as (number of women stating that the condition was “unproblematic” after the treatment) | 3 | 1 | 9.4 | 3.1 | 3.0
N = 122 | | | | | | | | (0.3; 27.3)
Arvonen, 2001 ^527^ | Pelvic floor muscle training program with contractions/relaxations for 5 seconds 10 times 2 times/day | Pelvic floor muscle training program with contractions/relaxations for 20/20 seconds 10 times 2 times/day using weighted vaginal balls 50–100g | Cured from stress urinary incontinence | 0 | 4 | 0.0 | 22.2 | 0.1 (0.0; 1.8)
N = 37

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control -rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F88 Effects of behavioral interventions on improvement of urinary continence in females (events) (tables sorted by rate of improvement in urinary continence after active treatments, from highest to lowest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Wells, 1991 ^520^ | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 90–160 times/day | Phenylpropanolamine hydrochloride in a dose of 50mg/day, increasing to 50mg 2 times/day | Negative simple lying stress test | 77 | 70 | 94.1 | 93.8 | 1.0 (0.9; 1.1)
N = 157
Janssen, 2001 ^508^ | Individual pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 11 30 minute sessions. | Group pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 9 2 hour sessions | % improved for urinary incontinence at 3 months | 118 | 347 | 94.0 | 86.0 | 1.1 (1.0; 1.2) | 13 (7; 44) | 80 (23; 136)E
N = 530
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) and pelvic floor electrical stimulation | Self-administered behavioral training administered with a self-help booklet | % of patients with >50% reduction in weekly incontinence episodes | 58 | 38 | 86.0 | 57.0 | 1.5 (1.2; 1.9) | 3 (2; 8) | 290
N = 200 | | | | | | | | | | (122; 524)E
Janssen, 2001 ^508^ | Individual pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 11 30 minute sessions. | Group pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 9 2 hour sessions | % improved for urinary incontinence at 9 months | 107 | 315 | 85.0 | 78.0 | 1.1 (1.0; 1.2) | 14 (7; 279) | 70 (4; 150)E
N = 530
Lagro-Janssen, 1991 ^525^ | Instructions in pelvic floor exercises 5–10 sessions of 10 pelvic muscle contractions for 6 seconds each day. | No therapy | Improvement in urinary incontinence | 28 | 0 | 85.0 | 0 | 57.0 | 1 (1; 381) | 849 (3; 895)E
N = 66 | | | | | | | | (3.6; 896.4)
Goode, 2002 ^501^ | Four sessions (over 8 weeks) of biofeedback-assisted behavioral training by nurse practitioners. | Usual care | Self reported improvement in urinary incontinence | 27 | 19 | 82.3 | 51.5 | 1.6 (1.1; 2.3) | 3 (2; 16) | 308 (62; 652)E
N = 70
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) | Self administered behavioral training administered with a self-help booklet | % of patients with >50% reduction in weekly incontinence episodes | 53 | 38 | 80.0 | 57.0 | 1.4 (1.1; 1.8) | 4 (2; 16) | 230 (64; 457)E
N = 200
Lagro-Janssen, 1991 ^525^ | Instructions in pelvic floor exercises 5–10 sessions of 10 pelvic muscle contractions for 6 seconds each day. | No therapy | Improvement in restrictions of activities | 25 | 2 | 75.0 | 6.0 | 12.5 | 1 (0;8) | 690
N = 66 | | | | | | | | (3.2; 48.6) | | (133; 2,854)E
Fantl, 1991 ^503^ | Bladder training using 6 weekly visits included patient education; voiding schedule to have micturition from every 30–60 minutes to every 2.5–3 hours; and positive reinforcement. | Usual care | Self reported more than 50% reduction in urinary incontinence episodes | 49 | 16 | 75.0 | 24.0 | 3.1 (2.0; 4.9) | 2 (1; 4) | 510
N = 131 | | | | | | | | | | (237; 929)E
Lagro-Janssen, 1992 ^502^ | Pelvic floor exercises alone (stress) or bladder training (urge) or its combination (mixed) | Usual care | Self reported improvement in urinary incontinence | 40 | 2 | 74.0 | 3.0 | 20.7 | 1 (0; 8) | 710
N = 106 | | | | | | | | (5.3; 81.6) | | (128; 2,419)E
Berghmans, 1996 ^522^ | Pelvic floor muscle exercise with biofeedback with EMG vaginal probe and visual control. | Pelvic floor muscle exercise | Improvement in stress urinary incontinence | 14 | 14 | 70.0 | 70.0 | 1.0 (0.7; 1.5)
N = 40
Lagro-Janssen, 1991 ^525^ | Instructions in pelvic floor exercises 5–10 sessions of 10 pelvic muscle contractions for 6 seconds each day. | No therapy | Improvement in psychological impact of urinary incontinence | 23 | 0 | 70.0 | 0.1 | 47.0 | 1 (1;507) | 699 (2; 742)E
N = 66 | | | | | | | | (3.0; 743.0)
Burns, 1990 ^519^ | Biofeedback with vaginal EMG probe and visual control | Usual care. | Self reported reduction in urine loss | 24 | 0 | 61.0 | 0.1 | 49.0 | 2 (1; 480) | 609 (2; 778)E
N = 128 | | | | | | | | (3.1; 779.1)
Burns, 1993 ^517^ | Biofeedback using vaginal EMG probe, contraction for 10 seconds and relaxations for 10 seconds 10 times in each weekly session | Usual care | Improvement in stress urinary incontinence | 24 | 2 | 61.0 | 6.0 | 11.7 | 2 (0; 8) | 550
N = 135 | | | | | | | | (3.0; 46.2) | | (118; 2,712)E
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) and pelvic floor electrical stimulation | Self-administered behavioral training administered with a self-help booklet | % of patients with >75% reduction in weekly incontinence episodes | 40 | 30 | 60.0 | 45.0 | 1.3 (1.0; 1.9) | 7 (3; 53) | 150 (19; 385)E
N = 200
Burgio, 2002 ^505^ | 4 visits of behavioral training without biofeedback (verbal feedback based on vaginal palpation). Pelvic floor muscle exercise with 10 second contractions and 10 second relation for 45 minutes/day. | Self-administered behavioral treatment using a self-help booklet to advice pelvic floor exercise and bladder control | Urinary incontinence does not restrict daily activities | 43 | 31 | 58.1 | 41.3 | 1.4 (1.0; 2.0) | 6 (3; 274) | 168 (4; 396)E
N = 222
Arvonen, 2001 ^527^ | Pelvic floor muscle training program with contractions/relaxations for 5 seconds 10 times 2 times/day | Pelvic floor muscle training program with contractions/relaxations for 20/20 seconds 10 times 2 times/day using weighted vaginal balls 50–100g | Improvement in stress urinary incontinence | 11 | 7 | 57.9 | 38.9 | 1.5 (0.7; 3.0)
N = 37
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) | Self-administered behavioral training administered with a self-help booklet | % of patients with >75% reduction in weekly incontinence episodes | 38 | 30 | 57.0 | 45.0 | 1.3 (0.9; 1.8)
N = 200
Diokno, 2004 ^487^ | Behavioral modification program: pelvic floor muscle training, bladder training | Usual care | % of improved incontinence | 92 | 80 | 56.0 | 41.0 | 1.4 (1.1; 1.7) | 7 (3; 24) | 150 (42; 286)E
N = 359
Burns, 1993 ^517^ | Pelvic muscle exercise with 4 sets of 20 increasing by 10/sets until maximum 200 sets/day | Usual care | Improvement in stress urinary incontinence | 23 | 2 | 54.0 | 6.0 | 10.4 | 2 (0; 10) | 480
N = 135 | | | | | | | | (2.6; 41.4) | | (98; 2,424)E
Burns, 1990 ^519^ | Kegel pelvic floor exercises 4 times/day | Usual care | Self reported reduction in urine loss | 21 | 0 | 54.0 | 0.1 | 45.2 | 2 (1; 545) | 539 (2; 720)E
N = 128 | | | | | | | | (2.8; 721.0)
Subak, 2002 ^500^ | 6 weekly 20 minute group instructional sessions on bladder training by nurse educators and followed individualized voiding schedules | Usual care | Self reported reduction in mean number of incontinent episodes, % | 39 | 11 | 50.0 | 15.0 | 3.4 (1.9; 6.1) | 3 (1; 7) | 350
N = 152 | | | | | | | | | | (134; 772)E
Burgio, 2002 ^505^ | Biofeedback-assisted behavioral training implemented by nurse practitioners | Self administered behavioral treatment using a self-help booklet to advise pelvic floor exercise and bladder control | Urinary incontinence does not restrict daily activities | 36 | 31 | 49.3 | 41.3 | 1.2 (0.8; 1.7)
N = 222
| 4 visits of behavioral training without biofeedback (verbal feedback based on vaginal palpation). Pelvic floor muscle exercise with 10 second contractions and 10 second relation for 45 minutes/day. | Self administered behavioral treatment using a self-help booklet to advise pelvic floor exercise and bladder control | Self reported improvement in urinary incontinence as “much better” | 36 | 20 | 48.6 | 26.7 | 1.8 (1.2; 2.8) | 5 (2; 22) | 220 (46; 490)E
| Biofeedback-assisted behavioral training implemented by nurse practitioners | Self administered behavioral treatment using a self-help booklet to advise pelvic floor exercise and bladder control | Self reported improvement in urinary incontinence as “much better” | 33 | 20 | 45.2 | 26.7 | 1.7 (1.1; 2.7) | 5 (2; 48) | 185 (21; 444)E
Bo, 1999 ^513^ | Pelvic floor exercise with 8–12 contractions 3 times/day and in groups with skilled physical therapists 1/week. | Untreated control group offered the use of a continence guard | Urinary continence and almost continent | 12 | 1 | 41.4 | 3.1 | 13.2 | 3 (0;3 8) | 383
N = 122 | | | | | | | | (1.8; 95.6) | | (26; 2,957)E
Aksac, 2003 ^516^ | Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds, 10 times/session, 3 sessions/day) via digital palpation at home | Usual care | Improvement in stress urinary incontinence in pad test | 5 | 2 | 25.0 | 20.0 | 1.3 (0.3; 5.3)
N = 50
Wyman, 1998 ^491^ | Combination of bladder training and pelvic muscle exercise | Bladder training | % of reported 75–99% reduction in incontinence | 13 | 9 | 22.0 | 15.0 | 1.5 (0.7; 3.2)
N = 204 | Pelvic muscle exercise with biofeedback-assisted instruction | Bladder training | % of reported 75–99% reduction in incontinence | 14 | 9 | 22.0 | 15.0 | 1.5 (0.7; 3.3)
Wells, 1991 ^520^ | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 90–160 times/day | Phenylpropanola mine hydrochloride in a dose of 50mg/day, increasing to 50mg 2 times/day | Improvement in stress urinary incontinence | 17 | 29 | 21.0 | 39.0 | 0.5 (0.3; 0.9) | 6 (4; 24) | 180 (42; 264)A
N = 157
Aksac, 2003 ^516^ | Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds) via biofeedback (vaginal probe in EMG pressure mode) 3 times/week | Usual care | Improvement in stress urinary incontinence in pad test | 4 | 2 | 20.0 | 20.0 | 1.0 (0.2; 4.6)
N = 50
Bo, 1999 ^513^ | Electrical stimulation using vaginal intermittent stimulation with the MS 106 Twin at 50Hz 30 minutes/day. | Untreated control group offered the use of a continence guard | Urinary continence and almost continent | 3 | 1 | 9.4 | 3.1 | 3.0 (0.3; 27.3)
N = 122

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F89 Effects of bladder training and pelvic muscle floor exercises on progression of urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
McFall, 2000 ^469^ | Community-based intervention: bladder training, managing the urge to urinate, and performing pelvic muscle exercises | Usual care | Self reported bothersomeness of urinary incontinence | 42 | 62 | 58.9 | 85.2 | 0.7 (0.6; 0.9) | 4 (3; 8) | 263
N = 145 | | | | | | | | | | (124; 381)A
Fantl, 1991 ^503^ | Bladder training using 6 weekly visits included patient education; voiding schedule to have micturition from every 30–60 minutes to every 2.5–3 hours; and positive reinforcement. | Usual care | Self reported increase in episodes of urinary incontinence | 5 | 28 | 8.0 | 43.0 | 0.2 (0.1; 0.4) | 3 (3; 4) | 350
N = 131 | | | | | | | | | | (241; 398)A
McFall, 2000 ^469^ | Community-based intervention: bladder training, managing the urge to urinate, and performing pelvic muscle exercises | Usual care | Use absorbent pads for urinary incontinence | 39 | 56 | 54.0 | 77.0 | 0.7 (0.6; 0.9) | 4 (3; 14) | 230 (74; 345)A
N = 145
Arvonen, 2001 ^527^ | Pelvic floor muscle training program with contractions/relaxations for 5 seconds 10 times 2 times/day | Pelvic floor muscle training program with contractions/relaxations for 20/20 seconds 10 times 2 times/day using weighted vaginal balls 50–100g | Leakage >50g | 1 | 1 | 5.3 | 5.6 | 0.9 (0.1; 14.0)
N = 37
Bo, 2000 ^512^ | Pelvic floor muscle exercise with 8–12 maximum contractions in 3 series/day and 45 min/week group sessions | Untreated control group | Problem with interference with physical activity | 13 | 24 | 43.5 | 79.3 | 0.6 (0.4; 0.9) | 3 (2; 10) | 358
N = 59 | | | | | | | | | | (102; 507)A
| | | Problems because of avoiding places and situations | 8 | 10 | 28.0 | 34.4 | 0.8 (0.4; 1.8)
| | | Problems with interference with social life | 1 | 12 | 3.7 | 40.7 | 0.1 (0.0; 0.6) | 3 (2; 6) | 370
| | | | | | | | | | (154; 402)A
Lagro-Janssen, 1992 ^502^ | Pelvic floor exercises alone (stress) or bladder training (urge) or its combination (mixed) | Usual care | Self reported deterioration in urinary incontinence | 1 | 2 | 2.0 | 3.0 | 0.5 (0.0; 5.6)
N = 106
Bo, 2005 ^497^ | Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months | Home exercise groups | Self reported severe and very severe urinary incontinence 15 years followup | 1 | 7 | 4.8 | 26.9 | 0.2 (0.0; 1.3)
N = 47
Lagro-Janssen, 1992 ^502^ | Pelvic floor exercises alone (stress) or bladder training (urge) or its combination (mixed) | Usual care | Self reported severe urinary incontinence | 4 | 23 | 7.4 | 41.1 | 0.2 (0.1; 0.5) | 3 (3; 5) | 337
N = 106 | | | | | | | | | | (211; 383)A
Bo, 2005 ^497^ | Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months | Home exercise groups | Self reported urge incontinence 15 years followup | 3 | 10 | 14.3 | 38.5 | 0.4 (0.1; 1.2)
N = 47 | | | Stress urinary incontinence last month (n) 15 years followup | 19 | 21 | 90.5 | 80.8 | 1.1 (0.9; 1.4)
Bo, 2000 ^512^ | Pelvic floor muscle exercise with 8–12 maximum contractions in 3 series/day and 45 minutes/week group sessions | Untreated control group | Urinary incontinence with intercourse | 3 | 13 | 10.5 | 41.7 | 0.2 (0.1; 0.8) | 3 (3; 10) | 312
N = 59 | | | | | | | | | | (104; 385)A
Bo, 2005 ^497^ | Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months | Home exercise groups | Always pad use 15 years followup | 3 | 7 | 14.3 | 26.9 | 0.5 (0.2; 1.8)
N = 47
Aukee, 2004 ^494^ | Pelvic floor training by physiotherapist 5 times/12 weeks with home biofeedback | Home program with given verbal and written instructions for home practice | Gynecologic surgery at 1 year of followup. | 9 | 5 | 47.4 | 31.3 | 1.5 (0.6; 3.6)
N = 35
McClurg, 2006 ^510^ | Pelvic Floor Training and Advice and EMG Biofeedback | Pelvic Floor Training and Advice | Self reported urinary incontinence | 5 | 8 | 50.00 | 80.00 | 0.63 (0.31; 1.25)
N = 30
100% female
24 months
Mørkved, 2002 ^529^ | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day with a biofeedback apparatus | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day without biofeedback | UI is Minor problem | 17 | 18 | 32.08 | 36.00 | 0.89 (0.52; 1.53)
N = 103 | | | UI is Moderate problem | 8 | 5 | 15.09 | 10.00 | 1.51 (0.53; 4.31)
6 months | | | UI is Problematic | 3 | 6 | 5.66 | 12.00 | 0.47(0.1; 1.79
| | | UI is very problematic | 1 | 3 | 1.89 | 6.00 | 0.31
| | | | | | | | (0.03; 2.92)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F90 Behavioral interventions on risk and progression of stress urinary incontinence in males with prostate diseases

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Wille, 2003 ^530^ | 139 patients who underwent radical retropubic prostatectomy | 1 Instructions about postoperative pelvic muscle exercises.; 2 Instructions about postoperative, electrical stimulation (ES) for 15 minutes twice daily with frequency 27Hz, biphasic pulse shape with 1-second bursts, a 5-second pulse width and 2-second pulse trains. Intensity was controlled by each patient from 10% to 100%.; 3 Instructions about postoperative, electrical stimulation (ES) for 15 minutes twice daily and biofeedback (BFB) 15 minutes twice daily with stimulation time of 5 seconds, and contracting and relaxing time of 5 and 15 seconds. | Self reported urinary incontinence with symptom inventory. 20-minute pad test | No intention to treat.
RCT to examine the effects of pelvic muscle exercises, electrical stimulation and biofeedback on urinary incontinence after radical retropubic prostatectomy. | Exclusion criteria: Patient unwillingness to make 2 visits 3 and 12 months Postoperatively. | Treatment was started immediately after catheter removal and performed for 3 months. | Subjective continence - no or 1 pad used daily. | Open label.
Duration: 3 months | Loss of followup: 7.9% | | Objective continence-urine loss of less than 1gm. | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 12 months | | | | Sample size not justified.
Yokoyama, 2004 ^531^ | 36 patients with urinary incontinence after retropubic radical prostatectomy. | 1 Extracorporeal magnetic innervation (ExMI) using neocontrol system was used with 20 minute treatment sessions, 2/week for 2 months. The frequency of the pulse field was 10Hz for 10 minutes, followed by a second treatment at 50Hz for 10 minutes.; 2 Functional electrical stimulation (FES) using anal electrode and pulses of 20Hz square waves at a 300μs pulse duration were used for 15 minutes twice daily for 1 month.; 3 Control group: pelvic floor muscle exercises. | Self reported bladder diaries, 24-hour pad weight testing | No intention to treat.
RCT to examine the effects extracorporeal magnetic innervation and functional electrical stimulation on urinary incontinence after retropubic radical prostatectomy. | Exclusion criteria: <100g pad weight after the 24-hour pad test 1 day after removing the catheter, use of anticholinergic drugs. | | | Open label.
Duration: 1–2 months | Loss of followup: none | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 6 months | | | | Sample size not justified.
Filocamo, 2005 ^532^ | 300 consecutive patients who had undergone standard radical retropubic prostatectomy for clinical stage T1 or T2 prostate cancer. | 1 Early pelvic floor rehabilitation program after removal of the catheter with verbal explanations, palpation, and visualization of Kegel exercises: 3 sets of 10 contractions for 5 seconds and 10 seconds of muscular relaxation under digital anal control.; 2 No formal training in pelvic floor rehabilitation after catheter removal. | Self reported urinary incontinence using International | No intention to treat.
RCT to examine the effects of early pelvic floor muscle training on urinary incontinence after radical retropubic prostatectomy. | Exclusion criteria: Prior bladder or prostate surgery, prior urinary or fecal incontinence, neurogenic dysfunction of the lower urinary tract, and a preoperative history of overactive bladder. | | Continence Society (ICS)-male questionnaire. | Open label.
Duration of followup: 12 months | Loss of followup: 1% | | 1 hour and 24 hour pad test | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Moore, 1999 ^533^ | 63 patients >4 weeks after radical prostatectomy, with urinary incontinence (>2g of urine loss on pad test), within 12 hours drive of study center, not seeking other treatments, able to speak and read English and comply with the study protocol. | 1 Intensive pelvic muscle exercises conducted by a physiotherapist for 30 minutes 2/week: maximal contractions for 5 seconds, slow release and 10 seconds of muscular relaxation.; 2 Intensive pelvic muscle exercises conducted by a physiotherapist for 30 minutes 2/week: maximal contractions for 5 seconds, slow release and 10 seconds of muscular relaxation; plus electrical stimulation: 50Hz, biphasic pulse shape with 1 second bursts, 1 second width, and 1 second pulse trains.; 3 Standard treatment with verbal and written instructions about postoperative pelvic muscle exercises from urologist and from the nurses at the pre-admission clinic. | Urine symptom inventory. Continence: a loss of <2g of urine. | No intention to treat.
RCT to examine the effects of intensive pelvic muscle exercises and electrical stimulation on urinary incontinence after radical prostatectomy. | Exclusion criteria: Demand pacemaker, previous pelvic floor stimulation, active rectal lesions or infections, known detrusor instability. | | Socially acceptable continence: loss of <10g of urine. 24-hour pad test | Open label. Computer generated randomization with random numbers list. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
Duration: 12 weeks. | Loss of followup: 7.9% | | | Sample size justified.
Duration of followup: 8 months
Mathewson-Chapman, 1997 ^534^ | 53 patients after radical prostatectomy for localized prostate cancer. | 1 Education booklet and instruction for pelvic muscle exercises with biofeedback: maximal contractions for 10 seconds, slow release, and 10 seconds of muscular relaxation, 3 times/week.; 2 Standard care with no pelvic muscle exercises. All patients were recommended to limit coffee, tea, chocolate, alcohol, and over counter medication for bladder control. | Self reported in three-day bladder diaries length of time urine loss was experienced; 2) episodes and frequency of urine loss; and 3) ounces of urine lost and number of pads used. | No intention to treat.
RCT to examine the effects of pelvic muscle exercises with biofeedback on urinary incontinence after radical prostatectomy for localized prostate cancer. | Exclusion criteria: not reported | | | Open label.
Duration: 12 weeks | Loss of followup: none | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Floratos, 2002 ^535^ | 42 consecutive patients with urinary incontinence after radical retropubic prostatectomy for localized prostate cancer, able to participate in a learning program, in good general condition and willingness to participate in the study. | 1 Electromyographic biofeedback as learning tools for pelvic muscle exercises immediately after catheter removal: submaximal contractions 3–5 seconds, relaxation for 6–10 seconds, 80–100 times/day and 15 sessions of 2-channel electromyographic biofeedback (three times weekly, 30 minutes each).; 2 Verbal feedback as learning tools for pelvic muscle exercises immediately after catheter removal: submaximal contractions 3–5 seconds, relaxation for 6–10 seconds, 80–100 times/day. | Self reported in 3-day bladder diaries. | No intention to treat.
RCT to examine the effects of electromyographic biofeedback with verbal instructions as learning tools of pelvic muscle exercises on urinary incontinence after radical prostatectomy. | Exclusion criteria: Significant perioperative complications (ureteric or rectal injury, urine leakage from anastomosis, thrombo-embolism), history of preoperative incontinence and pelvic or lower urinary tract operations, psychiatric history. | | Continence: a loss of <1g of urine. 1 hour pad test | Open label.
Duration: 12 weeks. | Loss of followup: 2.4% | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 6 months | | | | Sample size not justified.
Van Kampen, 2000 ^536^ | 102 consecutive incontinent patients who had had radical retropubic prostatectomy for clinically localized prostate cancer, incontinent on day 15 after surgery after removal of the catheter, and who could comply with the ambulatory treatment schedule. | 1 Pelvic floor re-education program with active pelvic floor muscle exercises and biofeedback for as long as they were incontinent.; 2 Placebo electrotherapy (a false interferential current) via four skin electrodes, two placed on the abdomen and two on the adductor muscles of the thighs | Self reported urinary incontinence with a visual analogue scale (0=completely dry, 10=completely incontinent). 1 hour and 24 hour pad tests. | Intention-to-treat.
RCT to examine the effects of pelvic floor re-education for patients with urinary incontinence after radical prostatectomy. | Exclusion criteria: Continence | | | Single blind.
Duration of followup: 1 year | Loss of followup: 3.9% | | | Computer generated randomization with random permuted blocks. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Bales, 2000 ^537^ | 100 men with Stages T1c–T2c prostate cancer who were to undergo radical retropubic prostatectomy. | 1 Graded pelvic muscle exercise training with biofeedback 2–4 weeks before surgery 4 times/day until surgery and to resume exercises when the urethral catheter was removed following surgery. Surface electrodes were used to assess muscle strength and contractions of 5–10 seconds, and 10–15 repetitions were performed.; 2 Control group: Pelvic muscle exercises without biofeedback. | Self reported urinary continence: one pad or less/day, either because of minimal urine leakage or for security if no leakage was present, | No intention to treat.
RCT to examine the effects of preoperative biofeedback training on urinary continence in men undergoing radical prostatectomy. | Exclusion criteria: Preoperative radiotherapy or neoadjuvant hormonal blockade, transurethral resection of the prostate, pre-existing neurologic disease. | | | Open label.
Duration: 2–4 weeks. | Loss of followup: 3% | | | Randomization and allocation concealment not reported. Baseline data not reported.
Duration of followup: 6 months | | | | Sample size not justified.
Porru, 2001 ^538^ | 63 consecutive patients with bladder outflow obstruction and diagnosis of symptomatic benign prostatic hyperplasia after transurethral prostatectomy. | 1 Verbal instruction, feedback on contractions of pelvic floor muscles, and verbal reinforcement of appropriate responses to teach selective contractions of anal sphincter muscles and relaxation of abdominal muscles for 45 times/day, divided into 3 sessions of 15 exercises each.; 2 Standard care without instruction on pelvic floor muscle exercises. | Self reported urinary incontinence using The American Urological Association Symptom Score | Intention to treat not stated. Single blind.
RCT to examine the effects of pelvic floor muscle exercises on urinary incontinence in patients after transurethral prostatectomy. | Exclusion criteria: Age over 80 years old, history of urethral or pelvic surgery, neurogenic bladder, or prostatic carcinoma. | | | Randomization and allocation concealment not reported. Baseline data not reported.
Duration: 4 weeks | Loss of followup: Not reported | | | Sample size not justified.
Franke, 2000 ^539^ | 30 patients who underwent radical retropubic prostatectomy. | 1 Pelvic floor muscle exercises at home of 20 contractions 3 times/day, with 45 minute perineal patch, electromyography biofeedback behavioral therapy session and timed voiding schedule to decrease urgency and urge incontinence.; 2 Standard care without instruction on pelvic floor muscle exercises. | Self reported urinary incontinence and voiding diary and 48-hour pad test | No intention to treat.
RCT to examine the effects of biofeedback and pelvic floor exercises 6 weeks after radical prostatectomy on urinary incontinence. | Exclusion criteria: Previous transurethral prostatic resection, neurological condition affecting the urinary tract, residual urine greater than 50ml. or a urinary tract infection. | | | Open label.
Duration: 6 months | Loss of followup: Not reported | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Parekh, 2003 ^540^ | 38 consecutive patients scheduled to undergo radical prostatectomy. | 1 Physical therapy for a pelvic floor exercise program with 2 treatment sessions before surgery and every 3 weeks for 3 months after the catheter removal. A home exercise program was followed for 6 months or longer by patients requiring further physical therapy guidance.; 2 Standard care without instruction on pelvic floor muscle exercises. | Self reported urinary incontinence and number of pads used daily. Continence - 0 or 1 precautionary pad | No intention to treat.
RCT to examine the effects of physical therapy and pelvic floor exercises before and after radical prostatectomy on urinary incontinence. | Exclusion criteria: Prior bowel or bladder incontinence. | | | Open label.
Duration: 3 months | Loss of followup: Not reported | | | Randomization and allocation concealment not reported. Baseline data not reported.
Duration of followup: 6 months | | | | Sample size not justified.
Dorey, 2004 ^541^ | 55 men with erectile dysfunction. | 1 Pelvic floor muscle exercises including a strong post-void “squeeze out” pelvic floor muscle contraction, biofeedback, and suggestions for lifestyle changes.; 2 Advice on lifestyle changes | 24 hours, pad test, anal manometric outcomes. | No intention to treat.
RCT to examine the effects of pelvic floor muscle exercises and manometric biofeedback for post-micturition dribble in men with erectile dysfunction. | Exclusion criteria: Urological congenital abnormalities, neurological deficits, and previous urological surgery. | | | Single blind. Random number system of odd or even tickets not adequate.
Duration of followup: 3 months | Loss of followup: 9.1% | | | Allocation concealment not adequate. Sample size not justified.
Burgio, 2006 ^542^ | 125 continent men 53 to 68 years old who elected radical prostatectomy for prostate cancer. | 1 Single preoperative session of biofeedback assisted behavioral training plus daily home exercise daily until the surgery and after catheter removal: 45 pelvic floor muscle exercises in various positions, divided into 3 sessions of 15 exercises to contract sphincter muscles (2 –10-second contraction, 2–10 seconds of relaxation with immediate visual feedback of rectal pressure and external anal sphincter contractions using 3 small balloons).; 2 Usual care control condition, consisting of simple postoperative instructions to interrupt the urinary stream. | Self reported incontinence duration from bladder diaries, incontinence severity (the proportion with severe/continual leakage), Incontinence Impact Questionnaire, psychological distress (Hopkins Symptom Checklist) pad use, and health related quality of life (Medical Outcomes Study Short Form Health Survey). | Intention to treat.
RCT to examine the effects of preoperative biofeedback assisted behavioral training on urinary incontinence after radical prostatectomy. | Exclusion criteria: >2 episodes of urinary incontinence in the previous 6 months, documented incontinence in the bladder diary, prior prostatectomy, impaired mental status (score less than 20 on the Mini-Mental State Examination), <1 week before scheduled surgery. | | Self reported continence -3 consecutive 1-day diaries with no leakage or a 7-day diary with no leakage. | Single blind.
Duration of follow up: 6 months | Loss of follow up: 18.4% | | | Randomization with computer generated random numbers and block size of 4 stratified by age (<65 vs. ≥65 years) and tumor differentiation (Gleason score ≤5 vs. > 5). Allocation concealment not adequate. Baseline data confirmed the adequacy of randomization.
| | | | Sample size justified.

Table F91 Effects of behavioral interventions on urinary continence in males (events) (table sorted by rate of continence in the active group, from highest to lowest)

Author | Active Treatment | Control Treatment | Definition of Continence | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Filocamo, 2005 ^532^ | Early pelvic floor rehabilitation program after removal of the catheter with verbal explanations, palpation, and visualization of Kegel exercises: 3 sets of 10 contractions for 5 seconds and 10 seconds of muscular relaxation under digital anal control. | No formal training in pelvic floor rehabilitation after catheter removal | Self reported urinary continence | 148 | 132 | 98.7 | 88.0 | 1.1 (1.1; 1.2) | 9 (6; 21) | 107 (47; 170)E
N = 300
Mathewson-Chapman, 1997 ^534^ | Education booklet and instruction for pelvic muscle exercises with biofeedback: maximal contractions for 10 seconds, slow release and 10 seconds of muscular relaxation, 3 times/week. | Standard care with no pelvic muscle exercises. All patients were recommended to limit coffee, tea, chocolate, alcohol, and over counter medication for bladder control. | Self reported urinary continence | 26 | 24 | 96.3 | 100.0 | 1.0 (0.9; 1.1)
N = 53
Van Kampen, 2000 ^536^ | Pelvic floor re-education program with active pelvic floor muscle exercises and biofeedback for as long as they were incontinent. | Placebo electrotherapy (a false interferential current) via four skin electrodes, two placed on the abdomen and two on the adductor muscles of the thighs. | Self reported urinary continence | 48 | 42 | 95.0 | 81.0 | 1.2 (1.0; 1.4) | 7 (3; 340) | 140 (3; 286)E
N = 102
Yokoyama, 2004 ^531^ | Extracorporeal magnetic innervation (ExMI) using neocontrol system was used with 20 minute treatment sessions, 2/week for 2 months. The frequency of the pulse field was 10Hz for 10 minutes, followed by a second treatment at 50Hz for 10 minutes. | Pelvic floor muscle exercises | Urinary continence pad free | 11 | 10 | 91.7 | 83.3 | 1.1 (0.8; 1.5)
N = 36
Filocamo, 2005 ^532^ | Early pelvic floor rehabilitation program after removal of the catheter with verbal explanations, palpation, and visualization of Kegel exercises: 3 sets of 10 contractions for 5 seconds and 10 seconds of muscular relaxation under digital anal control. | No formal training in pelvic floor rehabilitation after catheter removal. | International Continence Society (ICS)-male questionnaire: completely dry | 134 | 101 | 89.3 | 67.3 | 1.3 (1.2; 1.5) | 5 (3; 9) | 220 (115; 338)E
N = 300
Wille, 2003 ^530^ | Instructions about postoperative pelvic muscle exercises | Instructions about postoperative, electrical stimulation (ES) for 15 minutes twice daily and biofeedback (BFB) 15 minutes twice daily with stimulation time of 5 seconds, and contracting and relaxing time of 5 and 15 seconds | Self reported urinary continence | 41 | 41 | 88.0 | 88.6 | 1.0 (0.8; 1.1)
N = 139
Bales, 2000 ^537^ | Graded pelvic muscle exercise training with biofeedback 2 to 4 weeks before surgery 4 times/day until surgery and to resume exercises when the urethral catheter was removed following surgery. | Pelvic muscle exercises without biofeedback | Self reported urinary continence | 44 | 48 | 88.0 | 96.0 | 0.9 (0.8; 1.0)
N = 100
Van Kampen, 2000 ^536^ | Pelvic floor re-education program with active pelvic floor muscle exercises and biofeedback for as long as they were incontinent. | Placebo electrotherapy (a false interferential current) via four skin electrodes, two placed on the abdomen and two on the adductor muscles of the thighs. | Self reported urinary continence in visual analogue scale 0–1 (0 = completely dry, 10 = completely incontinent). | 44 | 36 | 88.0 | 70.0 | 1.3 (1.0; 1.6) | 6 (3; 44) | 180 (23; 396)E
N = 102
Franke, 2000 ^539^ | Pelvic floor muscle exercises at home of 20 contractions 3 times/day with 45 minute perineal patch, electromyography biofeedback behavioral therapy session and timed voiding schedule to decrease urgency and urge incontinence. | Standard care without instruction on pelvic floor muscle exercises. | Self reported pad free condition | 13 | 13 | 86.0 | 88.0 | 1.0 (0.8; 1.3)
N = 30
Parekh, 2003 ^540^ | Physical therapy for a pelvic floor exercise program with and 2 treatment sessions before surgery and every 3 weeks for 3 months after catheter removal. A home exercise program. | Standard care without instruction on pelvic floor muscle exercises. | Self reported urinary continence diary) | 16 | 14 | 85.0 | 75.0 | 1.1 (0.8; 1.6)
N = 38 | | | Self reported urinary continence (<1 pad/day) | 16 | 15 | 84.2 | 78.9 | 1.1 (0.8; 1.4)
Wille, 2003 ^530^ | Instructions about postoperative and electrical stimulation (ES) for 15 minutes twice daily with frequency 27Hz, biphasic pulse shape with 1 second bursts, a 5 second pulse width and 2 second pulse trains. | Instructions about postoperative, electrical stimulation (ES) for 15 minutes twice daily and biofeedback (BFB) 15 minutes twice daily with stimulation time of 5 seconds, and contracting and relaxing time of 5 and 15 seconds. | Self reported Urinary continence | 37 | 41 | 81.0 | 88.6 | 0.9 (0.8; 1.1)
N = 139 | Instructions about postoperative pelvic muscle exercises | | Urinary continence in pad test | 36 | 42 | 76.7 | 90.5 | 0.8 (0.7; 1.0)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F92 Effects of behavioral interventions on progression of urinary incontinence in males (events)

Author | Active Treatment | Control Treatment | Definition of Continence | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Moore, 1999 ^533^ | Intensive pelvic muscle exercises conducted by a physiotherapist for 30 minutes 2/week plus electrical stimulation: 50Hz, biphasic pulse shape with 1 second bursts, 1 second width, and 1 second pulse trains. | Standard treatment with verbal and written instructions about postoperative pelvic muscle exercises from urologist and from the nurses at the pre-admission clinic | Self reported urinary incontinence that affected life | 6 | 3 | 31.6 | 14.3 | 2.2 (0.6; 7.6)
N = 63 | Intensive pelvic muscle exercises conducted by a physiotherapist for 30 minutes 2/week: maximum contractions for 5 seconds, slow release and 10 seconds of muscular relaxation | Standard treatment with verbal and written instructions about postoperative pelvic muscle exercises from urologist and from the nurses at the pre-admission clinic | Self reported urinary incontinence that affected life | 3 | 3 | 16.7 | 14.3 | 1.2 (0.3; 5.1)
Porru, 2001 ^538^ | Verbal instruction, feedback on contractions of pelvic floor muscles, and verbal reinforcement of appropriate responses to teach selective contractions of anal sphincter muscles and relaxation of abdominal muscles, 45 times/day | Standard care without instruction on pelvic floor muscle exercises | Self reported urinary incontinence | 4 | 12 | 13.3 | 42.9 | 0.3 (0.1; 0.9) | 3 (3; 16) | 295 (53; 380)A
N = 58
Parekh, 2003 ^540^ | Physical therapy for a pelvic floor exercise program with and 2 treatment sessions before surgery and every 3 weeks for 3 months after catheter removal. A home exercise program. | Standard care without instruction on pelvic floor muscle exercises | Use of >3 pads/day for urinary incontinence | 2 | 3 | 10.5 | 15.8 | 0.7 (0.1; 3.5)
N = 38
Wille, 2003 ^530^ | Instructions about postoperative and electrical stimulation (ES) for 15 minutes twice daily with frequency 27Hz, biphasic pulse shape with 1 second bursts, a 5-second pulse width, and 2 second pulse trains. | Instructions about postoperative, electrical stimulation (ES) for 15 minutes twice daily and biofeedback (BFB) 15 minutes twice daily with stimulation time of 5 seconds; contracting and relaxing time of 5 and 15 seconds. | Urinary continence in pad test | 38 | 42 | 82.0 | 90.5 | 0.9 (0.8; 1.1)
N = 139
Dorey, 2004 ^541^ | Pelvic floor muscle exercises including a strong post-void “squeeze out” pelvic floor muscle contraction, biofeedback, and suggestions for lifestyle changes. | Advice on lifestyle changes | Less amount of post-micturition dribble | 2 | 1 | 7.1 | 3.7 | 1.9 (0.2; 20.1)
N = 55 | | | Less often post-micturition dribble | 2 | 2 | 7.1 | 7.4 | 1.0 (0.1; 6.4)
| | | No post-micturition dribble | 14 | 1 | 50.0 | 3.7 | 13.5 (1.9; 95.7) | 2 (0; 30) | 463 (33; 3,508)E
Filocamo, 2005 ^532^ | Early pelvic floor rehabilitation program after removal of the catheter with verbal explanations, palpation, and visualization of Kegel exercises: 3 sets of 10 contractions for 5 seconds and 10 seconds of muscular relaxation under digital anal control. | No formal training in pelvic floor rehabilitation after catheter removal | International Continence Society (ICS)-male questionnaire: 2 pads /day | 1 | 11 | 0.7 | 7.3 | 0.1 (0.0; 0.7) | 15 (14; 45) | 67 (22; 72)A
N = 300 | | | ICS-male questionnaire: 3 pads /day or more | 8 | 8 | 5.3 | 5.3 | 1.0 (0.4; 2.6)
| | | ICS male questionnaire: occasional leakage | 14 | 29 | 9.3 | 19.3 | 0.5 (0.3; 0.9) | 10 (7; 42) | 100 (142; 24)
| | | Self reported urinary incontinence | 2 | 18 | 1.3 | 12.0 | 0.1 (0.0; 0.5) | 9 (9; 16) | 107 (117; 64)
| | | Severe stress urinary incontinence that required implantation of artificial sphincter | 2 | 3 | 1.3 | 2.0 | 0.7 (0.1; 3.9)
Burgio; 2006 ^542^ | Single preoperative session of biofeedback assisted behavioral training plus daily home exercise. | Usual care control condition, consisting of simple postoperative instructions to interrupt the urinary stream | Urine loss when coughing | 11 | 24 | 17.46 | 38.71 | 0.45 (0.24; 0.84) | 5 (3; 16) | 212 (62; 293)A
N = 125 | | | Urine loss when sneezing | 13 | 23 | 20.63 | 37.10 | 0.56 (0.31; 1.00) | 6 (4; 709) | 165 (1; 256)A
6 months | | | Urine loss when Getting up from lying position | 7 | 15 | 11.11 | 24.19 | 0.46 (0.20; 1.05)
| | | Urine loss when lifting | 23 | 26 | 36.51 | 41.94 | 0.87 (0.56; 1.35)
| | | Urine loss when walking | 10 | 17 | 15.87 | 27.42 | 0.58 (0.29; 1.16)
| | | Urge to urinate on way to toilet | 13 | 19 | 20.63 | 30.65 | 0.67 (0.37; 1.24)
| | | Wearing pads | 16 | 24 | 25.40 | 38.71 | 0.66 (0.39; 1.11)
| | | Resume usual activities | 28 | 33 | 44.44 | 53.23 | 0.84 (0.58; 1.20)
| | | Severe and continual leakage | 4 | 12 | 5.90 | 19.80 | 0.33 (0.11; 0.96) | 7 (6; 133) | 139 (8; 176)A

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F93 Behavioral clinical interventions on urinary incontinence in adults

Study | Participants | Clinical Interventions | Outcome | Quality Issues
O'Brien, 1991 ^309^ | 561 adults ages 35 years and older with regular urinary incontinence (two or more leaks in any one month). | 1 Four sessions of pelvic floor exercises and bladder retraining supervised by non-specialist nurse.; 2 Usual care | Self reported urinary incontinence and changes in incontinence. | No Intention to treat.
RCT to examine the effects of pelvic floor exercises and bladder retraining supervised by non-specialist nurse on urinary incontinence in adults with regular urinary incontinence. | Exclusion criteria: Urinary tract infection. | | | Single blind.
Duration: 3 months | Loss of followup: not reported | | | Computer based randomization.
| | | | Allocation concealment unclear.
| | | | Baseline data not reported. Sample size justified.
McDowell, 1999 ^543^ | 105 adults 60 years and older, homebound (Health Care Financing Administration, cognitively intact (Folstein Mini-Mental State Examination score >24), with urinary incontinence (>2 urinary accidents/week for at least 3 months), who understand and speak English. | 1 Biofeedback-assisted pelvic floor muscle training by NPs skilled in behavioral therapies for urinary incontinence. Behavioral therapy: 8 weekly sessions at homes with biofeedback-assisted pelvic floor muscle exercises, urge and stress strategies, and bladder retraining. Biofeedback with surface electromyography for immediate visual and/or auditory feedback of pelvic floor and abdominal muscle activity. PFM exercises 3/day, 10–15 exercises at each session to contract and relax muscles for 10 seconds.; 2 Usual care with attention control (visits by the NP every 1–2 weeks to provide social interaction). | Self reported episodes of urinary incontinence/day and changes in severity of urinary incontinence (mild: <5 accidents/week; moderate: 5–10 accidents/week; severe: >10 accidents/week). | No intention to treat.
Cross-over RCT to examine the effects of behavioral therapies of urinary incontinence in homebound older adults. | Exclusion criteria: Folstein MMSE scores <24, severe pelvic prolapse, terminal illness, post-void residual >100ml unable to toilet independently, no caregiver willing and able to assist with toileting, <2 urinary accidents per week, unable to provide satisfactory self-report bladder diary data after three attempts. | | | Single blind.
Duration: 8 weeks. | Loss of followup: 19% | | | Computer-generated stratified by cognitive ability, toileting skills, and severity of urinary incontinence randomization with permuted blocks.
| | | | Allocation concealment unclear.
| | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Engberg, 2002 ^544^ , part of McDowell, 1999{McDowell, 1999 #10200} | 19 adults 60 years and older with urinary incontinence >2 episodes/week for >3 months who met Center for Medicare and Medicaid Services criteria for being homebound, residents in 2 large Medicare-approved home health agencies in a large metropolitan area who understand and speak English. | 1 Prompted voiding by caregivers to approach subjects hourly for perceived wet/dry status vs. objective wet checks, feedback and praising for correct response, toilet by request, positive feedback for appropriate toileting.; 2 Usual care with attention control (visits by the NP every 1–2 weeks to provide social interaction). | Incontinent episodes reported by subjects' caregivers in 2-week bladder diary. | Intention to treat.
Cross-over RCT to examine the effects of prompted voiding in cognitively impaired homebound older adults. | Exclusion criteria: Terminal illness; postvoid residual volume >100ml; caregiver was unable or unwilling to provide toileting assistance, complete bladder diaries, or implement the PV protocol. | | | Single blind.
Duration: 8 weeks | Loss of followup: 19% | | | Computer-generated stratified by cognitive ability, toileting skills, and severity of urinary incontinence randomization.
| | | | Allocation concealment unclear.
| | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified but power reported.
Paterson, 1997 ^545^ | 49 men 36–83 years old who had not undergone surgery on the bladder, urethra, or prostate gland but with history of post-micturition dribble. | 1 Pelvic muscle exercise with 1 second contractions (~5) to increase length and strengths of contractions as much as possible.; 2 Urethral milking after appropriate education.; 3 Counseling including drinking pattern, aperient use, toileting habits, dietary advice, and relaxation therapy. | Objectively measure pad weight gain. | No intention to treat.
RCT to examine the effects of pelvic floor exercises and urethral milking as treatments for post-micturition dribble in males. | Exclusion criteria: not reported. | | | Single blind.
Duration: 12 weeks. | Loss of followup: 12.2% | | | Randomization with random numbers table and balanced block design.
| | | | Allocation concealment unclear.
| | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.

Table F94 Effects of behavioral interventions on urinary incontinence in adults (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
O'Brien, 1991 ^309^ | Four sessions of pelvic floor exercises and bladder retraining supervised by non-specialist nurse | Usual care | Self reported improved urinary incontinence | 182 | 7 | 48.1 | 3.8 | 12.6 (6.0; 26.2) | 2 (1; 5) | 443 (193; 965)E
N = 561 | | | Self reported cured urinary incontinence | 32 | 1 | 8.5 | 0.5 | 15.5 (2.1; 112.5) | 13 (2; 161) | 79 (6; 609)E
76% female

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A- avoided; E- excessive events

Table F95 Effects of behavioral interventions on perceived urinary incontinence in females (severity and quality of life measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Baseline (95% CI)
Sample
Dougherty, 2002 ^504^ | Behavioral management for continence: self-monitoring, bladder training, pelvic muscle exercise | Usual care | Urine loss per 24 hours (g) at 6 months | 38.2 ± 109.9 | 37.2 ± 73.4 | 0.0 (-0.3; 0.3) | 0.0 (-0.8; 0.8)
N = 218 | | | Incontinence episodes/day at 6 months | 1.0 ± 1.9 | 1.8 ± 1.9 | -0.4 (-0.7; -0.1) | -23.4 (-39.9; -6.9)
| | | Nocturnal voluntary at 6 months | 0.5 ± 0.8 | 0.9 ± 0.8 | -0.5 (-0.8; -0.2) | -55.6 (-88.8; -22.3)
| | | Voiding interval (hours) at 6 months | 2.5 ± 0.7 | 2.4 ± 0.6 | 0.2 (-0.1; 0.4) | 6.4 (-5.9; 18.6)
| | | Self-rating of urine loss 6 months | 5.9 ± 0.9 | 4.7 ± 1.2 | 1.2 (0.9; 1.5) | 26.1 (19.2; 33.0)
| | | Nocturnal voluntary micturition per night at 2 years | 0.9 ± 1.0 | 1.3 ± 0.9 | -0.4 (-0.7; -0.1) | -32.2 (-55.1; -9.4)
| | | Voiding interval (hours) at 2 years | 2.3 ± 0.6 | 2.1 ± 0.6 | 0.3 (0.0; 0.6) | 15.9 (1.8; 30.0)
| | | Incontinence episodes/day at 2 years | 1.0 ± 1.2 | 2.3 ± 3.2 | -0.5 (-0.8; -0.3) | -23.9 (-36.9; -10.9)
| | | Self rating of urine loss at 2 years | 5.7 ± 1.3 | 4.9. ± 1.4 | 0.6 (0.3; 0.9) | 11.3 (5.2; 17.4)
Bo, 1999 ^513^ | Pelvic floor exercise with 8–12 contractions 3 times/day and in groups with skilled physical therapists 1/week. | Untreated control group offered the use of a continence guard | Change from baseline in episodes of leakage/day (average from 3 days) | -1.2 ± 2.0 | 0.3 ± 2.3 | -0.7 (-1.2; -0.2) | -228.8 (-401.3; -56.2)
N = 122 | Electrical stimulation using vaginal intermittent stimulation with the MS 106 Twin at 50Hz 30 minutes/day. | | | -0.7 ± 4.6 | 0.3 ± 2.3 | -0.3 (-0.8; 0.2) | -91.7 (-255.8; 72.4)
| | | Change from baseline in leakage index | -0.2 ± 0.5 | 0.1 ± 0.6 | -0.6 (-1.1; -0.1)
| | | Change from baseline in social activity index | 0.6 ± 1.0 | -0.2 ± 1.7 | 0.6 (0.1; 1.1) | -281.4 (-31.5; -531.4)
Liebergall-Wischnitzer, 2005 ^523^ | Pelvic floor muscle exercise 15 minutes with 30 minute lesson session/week | Paula method of circular muscle training 15–45 minutes/day with training sessions of 45 minutes/week | Change from baseline in quality of life-avoidance, limiting behaviors scores (8 items) | 9.5 ± 27.4 | 9.8 ± 17.3 | 0.0 (-0.5; 0.5) | -0.1 (-5.2; 4.9)
N = 63 | | | Change from baseline in quality of life-avoidance, social embarrassment scores (5 items) | 9.3 ± 13.0 | 14.0 ± 23.0 | -0.3 (-0.7; 0.2) | -1.8 (-5.3; 1.8)
Tibaek, 2005 ^499^ | Intensive pelvic floor muscle training 1–2 times/day by specialized physiotherapist | Usual care | Voiding frequency totally/24 hours | 7.0 ± 1.3 | 9.0 ± 2.7 | -1.0 (-1.8; -0.2) | -10.8 (-19.9; -1.7)
N = 26 | | | Voiding frequency, nighttime/24 hours | 2.0 ± 0.0 | 2.0 ± 0.7
| | | Number of used pads/24 hours | 1.0 ± 0.0 | 1.0 ± 1.3
| | | Number of incontinence episodes/24 hours | 0.0 ± 0.0 | 0.0 ± 0.7
Subak, 2002 ^500^ | 6 weekly 20-minute group instructional sessions on bladder training by nurse educators and followed individualized voiding schedules | Usual care | Diurnal incontinent episodes per week | 4.2 ± 5.5 | 9.6 ± 16.0 | -0.5 (-0.8; -0.1) | -4.7 (-8.1; -1.4)
N = 152 | | | Nocturnal incontinent episodes per week | 1.1 ± 2.0 | 1.4 ± 2.5 | -0.1 (-0.5; 0.2) | -9.5 (-32.2; 13.3)
| | | Total incontinent episodes per week | 5.2 ± 6.8 | 11.0 ± 17.4 | -0.4 (-0.8; -0.1) | -4.0 (-6.9; -1.1)
| | | Nocturnal micturition per week | 9.5 ± 5.2 | 6.7 ± 4.1 | 0.6 (0.3; 0.9) | 8.9 (4.1; 13.8)
Burgio, 2002 ^505^ | Biofeedback-assisted behavioral training implemented by nurse practitioners | Self administered behavioral treatment using a self-help booklet to advice pelvic floor exercise and bladder control | Self reported urinary incontinence episodes/week | 6.1 ± 10.3 | 6.7 ± 11.4 | -0.1 (-0.4; 0.3) | -0.8 (-5.6; 4.0)
N = 222 | 4 visits of behavioral training without biofeedback (verbal feedback based on vaginal palpation). pelvic floor muscle exercise with 10 second contractions and 10 second relation for 45 minutes/day | | % reduction in self reported urinary incontinence | 63.1 ± 42.7 | 58.6 ± 38.8 | 0.1 (-0.2; 0.4) | 0.2 (-0.4; 0.7)
| | | Self reported urinary incontinence episodes/week | 17.3 ± 16.3 | 15.4 ± 14.2 | 0.1 (-0.2; 0.4) | 0.8 (-1.3; 2.9)
| | | % reduction in self reported urinary incontinence | 69.4 ± 32.7 | 58.6 ± 38.8 | 0.3 (0.0; 0.6) | 0.5 (0.0; 1.1)
Wyman, 1997 ^506^ | Bladder training: patient education, progressive scheduled voiding regimen, positive reinforcement | Usual care | Self reported quality of life measures (Incontinence Impact Questionnaire (IIQ) | 32.0 ± 41.0 | 60.0 ± 65.0 | -0.5 (-0.9; -0.2) | -0.9 (-1.4; -0.3)
N = 131
Lagro-Janssen, 1991 ^525^ | Instructions in pelvic floor exercises 5–10 sessions of 10 pelvic muscle contractions for 6 seconds each day. | No therapy | Mean leakage episodes/week | 4.8 ± 1.3 | 25.3 ± 3.6 | -7.6 (-8.9; -6.2) | -29.8 (-35.4; -24.3)
N = 66
Theofrastous, 2002 ^492^ | Pelvic floor muscle training: 4 office biofeedback sessions and home exercise | Bladder training | Self reported urinary incontinent episodes per week | 9.4 ± 14.0 | 10.0 ± 12.0 | 0.0 (-0.4; 0.3) | -0.5 (-3.8; 2.9)
N = 137
Fantl, 1991 ^503^ | Bladder training using 6 weekly visits included patient education; voiding schedule to have micturition from every 30–60 minutes to every 2.5–3 hours; and positive reinforcement. | Usual care | Diurnal micturition/week | 52.0 ± 14.0 | 57.0 ± 27.0 | -0.2 (-0.6; 0.1) | -0.4 (-1.0; 0.2)
N = 131 | | | Nocturnal micturition/week | 5.0 ± 5.0 | 8.0 ± 6.0 | -0.5 (-0.9; -0.2) | -6.8 (-11.1; -2.4)
Diokno, 2004 ^487^ | Behavioral modification program: pelvic floor muscle training, bladder training | Usual care | Change in pressure digital scores adjusted for baseline difference in this variable | | | -0.49 (-35.7; 34.7)
N = 359 | | | Change in displacement digital scores adjusted for baseline difference in this variable | | | -0.57 (-42.8; 41.6)
| | | Change in 24 hour urinary frequency adjusted for baseline difference in this variable | | | -0.35 (-13.3; 12.6)
| | | Change in intervoid interval adjusted for baseline difference in this variable | | | -0.39 (-14.9; 14.1)
Yoon, 2003 ^507^ | Bladder training with increased interval between voluntary voids. | Usual care | Nocturia (number/night) | 0.7 ± 0.8 | 1.5 ± 1.0 | -0.9 (-1.7; -0.1) | -59.2 (-114.2; -4.1)
N = 50 | | | Leaked urine: amount (g) | 4.6 ± 6.2 | 8.4 ± 9.8 | -0.5 (-1.3; 0.3) | -5.6 (-15.0; 3.9)
| | | Leaked urine: amount ratio (g/ml) | 0.0 ± 0.0 | 0.0 ± 0.0 | -0.4 (-1.2; 0.4)
| | | Urinary incontinence scores | 12.1 ± 7.8 | 14.2 ± 3.6 | -0.3 (-1.1; 0.4) | -2.4 (-8.0; 3.2)
| Pelvic muscle exercise (30 contractions for 15–20 minutes/day) with immediate and simultaneous visual feedback of pelvic muscles during a 20 minute weekly biofeedback session with electromyography. | Usual care | Leaked urine, amount (g) | 3.3 ± 4.5 | 8.4 ± 9.8 | -0.7 (-1.5; 0.1) | -8.1 (-17.7; 1.6)
| | | Leaked urine, amount ratio (g/ml) | 0.0 ± 0.0 | 0.0 ± 0.0 | -0.8 (-1.6; 0.0)
| | | Nocturia (number/night) | 1.9 ± 1.1 | 1.5 ± 1.0 | 0.4 (-0.4; 1.2) | 25.3 (-27.5; 78.1)
| | | Urinary incontinence scores | 10.8 ± 6.2 | 14.2 ± 3.6 | -0.7 (-1.5; 0.1) | -4.7 (-10.4; 1.0)
Janssen, 2001 ^508^ | Individual pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 11 30-minute sessions. | Group pelvic floor exercises 5 times/day and bladder training with delay voiding, training with 9 2-hour sessions | Mean (SD) number of times of nocturnal loss/month at 9 months | 2.5 ± 8.7 | 6.1 ± 12.2 | -0.3 (-0.5; -0.1) | -5.1 (-8.4; -1.9)
N = 530 | | | Mean (SD) number of times of urine loss/week at 3 months | 7.3 ± 12.0 | 6.0 ± 9.3 | 0.1 (-0.1; 0.3) | 2.2 (-1.2; 5.5)
| | | Mean (SD) number of times of urine loss/week at 9 months | 8.6 ± 15.5 | 6.1 ± 10.5 | 0.2 (0.0; 0.4) | 3.5 (0.2; 6.7)
| | | Mean (SD) number of times of nocturnal loss/month at 3 months | 8.3 ± 17.7 | 7.7 ± 17.0 | 0.0 (-0.2; 0.2) | 0.5 (-2.1; 3.1)
Wyman, 1998 ^491^ | The pelvic muscle exercise with biofeedback-assisted instruction | Bladder training | Self reported number of incontinence episodes/week | 9.6 ± 10.8 | 10.6 ± 16.3 | -0.1 (-0.4; 0.3) | -0.7 (-3.8; 2.5)
N = 204 | | | Self reported number of stress incontinence episodes/week | 8.7 ± 0.0 | 12.5 ± 8.3
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self monitoring with bladder diaries) and pelvic floor electrical stimulation | Self-administered behavioral training administered with a self-help booklet | Self reported % reduction in incontinent episodes/week | 71.9 ± 32.8 | 52.5 ± 42.7 | 0.5 (0.2; 0.9) | 1.0 (0.3;' 1.6)
N = 200 | | | Self-reported number of incontinent episodes/week | 5.6 ± 13.3 | 7.5 ± 12.1 | -0.1 (-0.5; 0.2) | -2.0 (-6.5; 2.5)
Cammu, 1998 ^514^ | Weekly session of pelvic floor exercises vaginal probe EMG biofeedback using perineometer | Vaginal weight cones (20, 32, 45, 57, and 70g) for 15 minutes, twice daily | Number leakages/week | 5.6 ± 5.5 | 8.7 ± 13.0 | -0.3 (-0.8; 0.2) | -3.6 (-9.4; 2.3)
N = 30 | | | Number pads/week | 6.0 ± 5.6 | 8.8 ± 13.0 | -0.3 (-0.8; 0.2) | -3.2 (-9.0; 2.6)
| | | Visual analogue scale (0–10) | 2.6 ± 2.1 | 2.9 ± 2.4 | -0.1 (-0.6; 0.4) | -4.6 (-22.1; 12.9)
| | | Visual analogue scale (0–10). Severity of incontinence | 2.1 ± 2.1 | 3.4 ± 3.3 | -0.5 (-1.0; 0.0) | -13.8 (-28.9; 1.3)
Wyman, 1998 ^491^ | Pelvic muscle exercise with biofeedback-assisted instruction | Bladder training | Self reported number of incontinence episodes/week | 9.6 ± 10.8 | 10.6 ± 16.3 | -0.1 (-0.4; 0.3) | -0.7 (-3.9; 2.5)
N = 204 | | | Self reported number of stress incontinence episodes/week | 8.7 ± 0.0 | 12.5 ± 8.3
Alewijnse, 2003 ^493^ | Pelvic floor muscle exercise and reminder intervention | Bladder training and pelvic floor muscle exercise | Wet episodes/week | 12.2 ± 16.6 | 8.8 ± 13.0 | 0.2 (-0.3; 0.8) | 2.6 (-3.7; 9.0)
N = 129 | Pelvic floor muscle exercise with reminder and self-help guide | Bladder training and pelvic floor muscle exercise | Wet episodes/week | 12.2 ± 16.6 | 8.8 ± 13.0 | 0.2 (-0.3; 0.8) | 2.6 (-3.5; 8.7)
| Pelvic floor muscle exercise with reminder, self-help guide and counseling intervention | Bladder training and pelvic floor muscle exercise | Wet episodes/week | 12.2 ± 16.6 | 8.8 ± 13.0 | 0.2 (-0.3; 0.8) | 2.6 (-3.4; 8.6)
Bo, 2000 ^512^ | Pelvic floor muscle exercise with 8–12 maximum contractions in 3 series/day and 45 minutes/week group sessions | Untreated control group | Quality of Life Scale | 90.1 ± 10.2 | 85.2 ± 12.0 | 0.4 (-0.1; 1.0) | 0.5 (-0.1; 1.1)
N = 59 | | | Change from baseline in leakage index | -0.9 ± 0.5 | 0.1 ± 0.6 | -1.8 (-2.4; -1.2)
| | | Change from baseline in social activity index | 0.6 ± 1.0 | -0.2 ± 1.7 | 0.6 (0.0; 1.1)
Sung, 2000 ^524^ | Functional electrical stimulation-biofeedback for 20 minutes/session with frequency 35Hz–50Hz and contractions of 32 seconds, 2 sessions/week | Usual care | Frequency of incontinence (5-very serious problem) | 1.8 ± 0.9 | 2.2 ± 0.5 | -0.5 (-1.1; 0.0) | -25.0 (-48.4; -1.5)
N = 90 | | | Quantity of urine leakage (5-very serious problem) | 1.8 ± 0.8 | 2.3 ± 0.5 | -0.7 (-1.3; -0.2) | -32.6 (-55.4; -9.8)
| | | Severity of incontinence (5-very serious problem) | 1.8 ± 0.8 | 2.2 ± 0.6 | -0.6 (-1.1; 0.0) | -25.7 (-49.2; -2.2)
| | | Discomfort due to incontinence (5-very serious problem) | 1.6 ± 1.1 | 1.5 ± 0.6 | 0.1 (-0.4; 0.6) | 7.5 (-26.2; 41.3)
| | | Wearing protection (5-very serious problem) | 1.3 ± 0.6 | 1.3 ± 0.5 | 0.0 (-0.5; 0.5) | 0.0 (-38.9; 38.9)
| | | Discomfort due to wearing protection (5-very serious problem) | 2.0 ± 0.5 | 2.2 ± 0.4 | -0.4 (-1.0; 0.1) | -20.1 (-43.4; 3.2)
| | | Avoidance of places and situations (5-very serious problem) | 1.4 ± 0.9 | 1.5 ± 0.8 | -0.1 (-0.6; 0.4) | -7.8 (-41.6; 25.9)
| Intensive pelvic floor muscle exercises | Usual care | Quantity of urine leakage (5-very serious problem) | 2.1 ± 0.5 | 2.2 ± 0.5 | -0.2 ( -0.7; 0.3) | -9.1 (-32.2; 14.0)
| | | Severity of incontinence (5-very serious problem) | 2.1 ± 0.7 | 2.3 ± 0.5 | -0.3 (-0.8; 0.2) | -14.3 (-36.5; 7.9)
| | | Discomfort due to incontinence (5-very serious problem) | 2.0 ± 0.7 | 2.2 ± 0.6 | -0.3 (-0.8; 0.2) | -13.9 (-37.1; 9.2)
| | | Wearing protection (5-very serious problem) | 1.4 ± 0.6 | 1.5 ± 0.6 | -0.2 (-0.7; 0.3) | -11.1 (-44.9; 22.7)
| | | Discomfort due to wearing protection (5-very serious problem) | 1.2 ± 0.4 | 1.3 ± 0.5 | -0.2 (-0.7; 0.3) | -17.0 (-56.0; 22.1)
| | | Frequency of incontinence (5-very serious problem) | 1.7 ± 1.0 | 2.2 ± 0.4 | -0.7 (-1.2; -0.1) | -29.8 (-53.5; -6.2)
| | | Avoidance of places and situations (5-very serious problem) | 1.4 ± 0.7 | 1.5 ± 0.8 | -0.1 (-0.6; 0.4) | -8.9 (-42.6; 24.9)
Aukee, 2002 ^521^ | Pelvic floor muscle exercise after verbal and written instructions for home practice of 20 minutes/day 5 times /week and individual EMG-assisted biofeedback device with vaginal probe and verbal control. | Pelvic floor muscle exercise after verbal and written instructions for home practice of 20 minutes/day 5 times/week | Leakage index | 34.9 ± 10.4 | 38.1 ± 10.5 | -0.3 (-1.0; 0.4) | -0.8 (-2.7; 1.1)
N = 30
Sherman, 1997 ^518^ | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 5 times/session, 20 minutes twice/day with urethral biofeedback using vaginal EMG probe. | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 5 times/session 20 minutes twice/day alone | Number of urinary leaks | 2.9 ± 6.5 | 5.3 ± 7.2 | -0.3 (-1.0; 0.3) | -6.6 (-18.8; 5.7)
N = 39 | | | Number of voids/night | 0.3 ± 0.5 | 0.3 ± 0.5 | 0.0 (-0.6; 0.7) | 7.9 (-247.3; 263.1)
Aksac, 2003 ^516^ | Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds, 10 times/session, 3 sessions/day) via digital palpation at home | Usual care | Visual analog scale based social activity index: 0 - cannot undertake any social activity, 10 - does not have any problem. | 7.5 ± 1.2 | 3.6 ± 0.6 | 3.7 (2.5; 5.0) | 103.6 (69.3′; 138.0)
N = 50 | | | Stress urinary incontinence frequency | 3.5 ± 0.5 | 2.4 ± 0.9 | 1.7 (0.8; 2.6) | 69.9 (33.4; 106.4)
| Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds) via biofeedback (vaginal probe in EMG pressure mode) 3 times/week | Usual care | Stress urinary incontinence frequency | 3.6 ± 0.4 | 2.4 ± 0.9 | 2.0 (1.1; 2.9) | 82.3 (44.0; 120.6)
| | | Visual analog scale based social activity index: 0 - cannot undertake any social activity, 10 - does not have any problem. | 8.1 ± 0.8 | 3.6 ± 0.6 | 6.1 (4.3; 7.8) | 168.5 (119.6; 217.5)
Wang, 2004 ^496^ | Biofeedback-assisted pelvic floor muscle training with an Intravaginal electromyogram probe to contract or relax PFMs following the visual EMG signals. | Pelvic floor muscle training | Episodes of leakage per day | 0.7 ± 1.8 | 0.7 ± 1.8 | 0.0 (-0.5; 0.4) | -2.3 (-63.1; 58.6)
N = 120
Borello-France, 2006 ^528^ | Pelvic-floor muscle exercises with EMG biofeedback in the supine position only using maximum 30–60 repetitions of 3–12 second contractions twice daily. | Pelvic-floor muscle exercises with EMG biofeedback in both supine and upright positions, 1 set (3-and 12-second contractions) in each position with maximum 20 repetitions (2 sets of 10) of the 3–12 second contractions twice daily | Change in Incontinence Impact Questionnaire score (400 with poorer perceived quality of life) | 27.6 ± 32.7 | 24.7 ± 31.0 | 0.1 (-0.5; 0.7) | 0.4 (-2.0; 2.8)
N = 44 | | | Change from baseline in amount of urine loss in pad test, g | 3.9 ± 3.8 | 5.1 ± 3.9 | -0.3 (-0.9; 0.3) | -6.1 (-17.8; 5.5)
| | | Change from baseline in urine leaks/week | 4.0 ± 4.7 | 5.4 ± 4.8 | -0.3 (-0.9; 0.3) | -5.5 (-16.5; 5.5)
Kim, 2001 ^526^ | Continence Efficacy Intervention Program: common pelvic floor muscle education, audiovisual tape, calendar, counseling, schedule guideline, assessing self care methods. | Conventional care. | Improved scores (from 0–100) | 37.8 ± 23.9 | 23.6 ± 18.9 | 0.7 (0.0; 1.4) | 2.8 (-0.2; 5.8)
N = 33
Mørkved, 2003 ^486^ | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day with a biofeedback apparatus | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day with a biofeedback apparatus | Leakage index | 1.90±0.74 | 1.90±0.72 | 0.00 (-0.39; 0.39)
N - 103 | | | Social activity index | 9.50±0.74 | 9.40±1.08 | 0.11 (-0.28; 0.50)
6 months | | | Standardized pad test | 6.10±11.14 | 10.60±20.92 | -0.27 (-0.66; 0.12) | -2.55 (-6.22; 1.11)
| | | 48-hr home pad test | 6.50±15.23 | 6.00±10.10 | 0.04 (-0.35; 0.42) | 0.64 (-5.80; 7.08)
McClurg, 2006 ^510^ | Pelvic Floor Training and Advice and EMG Biofeedback | Pelvic Floor Training and Advice | Incontinence Impact Questionnaire (IIQ) Scores: Total score | 62.50±44.20 | 101.60±46.10 | -0.87 (-1.79; 0.06) | -0.85 (-1.76; 0.05)
N = 30 | | | Incontinence Impact Questionnaire (IIQ) Scores: Physical activity | 32.90±37.10 | 35.60±25.70 | -0.08 (-0.96; 0.79) | -0.24 (-2.70; 2.23)
24 months | | | Incontinence Impact Questionnaire (IIQ) Scores: Emotional health | 28.70±39.20 | 28.70±26.00 | 0.00 (-0.88; 0.88) | 0.00 (-3.05; 3.05)
| | | Incontinence Impact Questionnaire (IIQ) Scores: Travel | 32.90±37.10 | 46.40±28.00 | -0.41 (-1.30; 0.48) | -0.89 (-2.80; 1.03)
| | | Incontinence Impact Questionnaire (IIQ) Scores: Social relationships | 28.80±39.30 | 14.90±12.40 | 0.48 (-0.41; 1.37) | 3.20 (-2.77; 9.18)
| | | Urogenital Distress Inventory (UDI) Scores: Total score | 77.90±33.50 | 139.60±66.50 | -1.17 (-2.13; -0.22) | -0.84 (-1.52; -0.15)
| | | Urogenital Distress Inventory (UDI) Scores: Irritative symptoms | 40.00±18.12 | 56.60±28.80 | -0.69 (-1.59; 0.22) | -1.22 (-2.82; 0.38)
| | | Urogenital Distress Inventory (UDI) Scores: Obstructive/discomfort | 23.70±18.20 | 49.10±36.10 | -0.89 (-1.81; 0.03) | -1.81 (-3.69; 0.07)
| | | Urogenital Distress Inventory (UDI) Scores: Stress symptoms | 19.90±23.30 | 47.50±34.70 | -0.93 (-1.86; 0.01) | -1.97 (-3.92; -0.01)
| | | Incontinence Impact Questionnaire (IIQ) Scores: Total score | 78.90±55.70 | 101.60±46.10 | -0.44 (-1.33; 0.44) | -0.44 (-1.31; 0.44)
| | | Incontinence Impact Questionnaire (IIQ) Scores: Physical activity | 27.00±30.50 | 35.60±25.70 | -0.30 (-1.19; 0.58) | -0.86 (-3.33; 1.62)
| | | | 28.50±29.50 | 28.70±26.00 | -0.01 | -0.03 (-3.08; 3.03)
| | | Incontinence Impact Questionnaire (IIQ) Scores: Emotional health | | | (-0.88; 0.87)
| | | Incontinence Impact Questionnaire (IIQ) Scores: Travel | 32.70±30.90 | 46.40±28.00 | -0.46 (-1.35; 0.42) | -1.00 (-2.92; 0.92)
| | | Incontinence Impact Questionnaire (IIQ) Scores: Social relationships | 25.00±30.60 | 14.90±12.40 | 0.43 (-0.46; 1.32) | 2.90 (-3.06; 8.86)
| | | Urogenital Distress Inventory (UDI) Scores: Total score | 100.50±43.10 | 139.60±66.50 | -0.70 (-1.60; 0.21) | -0.50 (-1.15; 0.15)
| | | Urogenital Distress Inventory (UDI) Scores: Irritative symptoms | 47.60±12.00 | 56.60±28.80 | -0.41 (-1.29; 0.48) | -0.72 (-2.29; 0.85)
| | | Urogenital Distress Inventory (UDI) Scores: Obstructive/discomfort | 31.50±22.80 | 49.10±36.10 | -0.58 (-1.48; 0.31) | -1.19 (-3.01; 0.64)
| | | Urogenital Distress Inventory (UDI) Scores: Stress symptoms | 23.20±26.20 | 47.50±34.70 | -0.79 (-1.70; 0.12) | -1.66 (-3.59; 0.26)

Bold- significant differences in outcomes at 95% confidence level

Table F96 Effects of behavioral interventions on the results of pad test and urodynamic and perineometry outcomes in females (objective severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Elser, 1999 ^498^ | Pelvic floor muscle training combined with bladder training | Bladder training | Mean Kegel urethral closure pressure | 19.0 ± 10.0 | 21.0 ± 13.0 | -0.2 (-0.5; 0.2) | -0.8 (-2.4; 0.8)
N = 204 | | | Mean pressure transmission ratio, % | 91.0 ± 15.0 | 87.0 ± 14.0 | 0.3 (-0.1; 0.6) | 0.3 (-0.1; 0.7)
| | | Urethral axis straining | 44.0 ± 21.0 | 40.0 ± 19.0 | 0.2 (-0.1; 0.5) | 0.5 (-0.3; 1.3)
| | | Maximum cystometric capacity | 470.0 ± 119.0 | 490.0 ± 139.0 | -0.2 (-0.5; 0.2) | 0.0 (-0.1; 0.0)
| | | Maximum Kegel urethral closure pressure | 32.0 ± 19.0 | 31.0 ± 17.0 | 0.1 (-0.3; 0.4) | 0.2 (-0.9; 1.3)
| | | Difference between MCC and FSV (MCC - FSV) | 185.0 ± 141.0 | 217.0 ± 156.0 | -0.2 (-0.6; 0.1) | -0.1 (-0.3; 0.1)
| | | Functional urethral length | 23.0 ± 7.0 | 22.0 ± 7.0 | 0.1 (-0.2; 0.5) | 0.6 (-0.9; 2.2)
| | | Maximum urethral closure pressure | 31.0 ± 2.0 | 32.0 ± 17.0 | -0.1 (-0.4; 0.3) | -0.3 (-1.3; 0.8)
| | | Mean urethral closure pressure | 19.0 ± 9.0 | 22.0 ± 13.0 | -0.3 (-0.6; 0.1) | -1.2 (-2.8; 0.3)
| | | First sensation to void | 278.0 ± 124.0 | 279.0 ± 133.0 | 0.0 (-0.3; 0.3) | 0.0 (-0.1; 0.1)
| | Pelvic floor muscle training | Mean Kegel urethral closure pressure | 19.0 ± 10.0 | 20.0 ± 11.0 | -0.1 (-0.4; 0.2) | -0.5 (-2.2; 1.2)
| | | Mean pressure transmission ratio, % | 91.0 ± 15.0 | 92.0 ± 17.0 | -0.1 (-0.4; 0.3) | -0.1 (-0.4; 0.3)
| | | Urethral axis straining | 44.0 ± 21.0 | 43.0 ± 20.0 | 0.0 (-0.3; 0.4) | 0.1 (-0.7; 0.9)
| | | Mean urethral closure pressure | 19.0 ± 9.0 | 19.0 ± 10.0 | 0.0 (-0.3; 0.3) | 0.0 (-1.8; 1.8)
| | | Maximum Kegel urethral closure pressure | 32.0 ± 19.0 | 30.0 ± 16.0 | 0.1 (-0.2; 0.5) | 0.4 (-0.7; 1.5)
| | | First sensation to void | 278.0 ± 124.0 | 258.0 ± 103.0 | 0.2 (-0.2; 0.5) | 0.1 (-0.1; 0.2)
| | | Maximum cystometric capacity | 470.0 ± 119.0 | 471.0 ± 141.0 | 0.0 (-0.3; 0.3) | 0.0 (-0.1; 0.1)
| | | Difference between MCC and FSV (MCC - FSV) | 185.0 ± 141.0 | 213.0 ± 147.0 | -0.2 (-0.5; 0.1) | -0.1 (-0.2; 0.1)
| | | Functional urethral length | 23.0 ± 7.0 | 21.0 ± 5.0 | 0.3 (0.0; 0.7) | 1.6 (0.0; 3.2)
| | | Maximum urethral closure pressure | 31.0 ± 2.0 | 35.0 ± 21.0 | -0.3 (-0.6; 0.1) | -0.8 (-1.7; 0.2)
Goode, 2002 ^501^ | Four sessions (over 8 weeks) of biofeedback-assisted behavioral training by nurse practitioners. | Usual care | First desire to void, ml | 115.9 ± 64.9 | 133.5 ± 59.6 | -0.3 (-0.8; 0.2) | -0.2 (-0.6; 0.1)
N = 70 | | | Strong desire to void | 228.9 ± 106.4 | 230.1 ± 78.8 | 0.0 (-0.5; 0.5) | 0.0 (-0.2; 0.2)
| | | Bladder capacity | 305.6 ± 117.9 | 323.0 ± 109.0 | -0.2 (-0.6; 0.3) | 0.0 (-0.2; 0.1)
Wang, 2004 ^496^ | Biofeedback-assisted pelvic floor muscle training with an Intravaginal electromyogram probe to contract or relax PFMs following the visual EMG signals. | Electrical stimulation in management of overactive bladder with Intravaginal electrode at physiotherapy unit | Change from baseline in vaginal pressure | -8.9 ± 12.8 | -38.4 ± 29.6 | 1.3 (0.8; 1.8) | -3.3 (-2.1; -4.6)
N = 120
Bo, 2005 ^497^ | Intensive pelvic floor exercise with 8–12 maximum contractions for 6–8 seconds 3 series/day under the supervision of physical therapist for 6 months | Home exercise groups | Median leakage index (range) 15 years followup | 1.9 ± 0.5 | 1.9 ± 1.9 | 0.0 (-0.6; 0.6) | 0.0 (-30.3; 30.3)
N = 47
Dougherty, 2002 ^504^ | Behavioral management for continence: self-monitoring, bladder training, pelvic muscle exercise | Usual care | Urine loss per 24 hours (g) at 2 years | 21.3 ± 36.4 | 130.9 ± 315.5 | -0.5 (-0.8; -0.2) | -0.4 (-0.6; -0.2)
N = 218
Yoon, 2003 ^507^ | Pelvic muscle exercise (30 contractions for 15 to 20 minutes/day) with immediate and simultaneous visual feedback of pelvic muscles during a 20 minute weekly biofeedback session with electromyography. | Usual care | Pelvic muscle contraction: average pressure (mm/Hg) | 26.1 ± 12.5 | 12.2 ± 5.3 | 1.4 (0.5; 2.3) | 11.7 (4.4; 19.0)
N = 50 | | | Pelvic muscle contraction: Index computed as average pressure multiplied by duration. | 392.4 ± 237.1 | 71.5 ± 26.4 | 1.9 (0.9; 2.8) | 2.6 (1.3; 3.9)
| | | Pelvic muscle contraction: Peak pressure (mm/Hg) | 39.7 ± 20.0 | 19.9 ± 7.5 | 1.3 (0.4; 2.2) | 6.5 (2.1; 10.8)
| | | Pelvic muscle contraction: duration(seconds) | 14.5 ± 3.0 | 5.9 ± 1.7 | 3.5 (2.2; 4.8) | 59.1 (37.5; 80.8)
| | | Voided volume (ml) | 239.7 ± 53.4 | 193.3 ± 37.8 | 1.0 (0.2; 1.8) | 0.5 (0.1; 0.9)
| Bladder training with increased interval between voluntary voids. | Usual care | Voided volume (ml) | 271.9 ± 47.3 | 193.3 ± 37.8 | 1.8 (0.9; 2.8) | 0.9 (0.5; 1.4)
| | | Pelvic muscle contraction: Peak pressure (mm/Hg) | 30.5 ± 9.1 | 19.9 ± 7.5 | 1.3 (0.4; 2.1) | 6.4 (2.0; 10.7)
| | | Pelvic muscle contraction: Average pressure (mm/Hg) | 18.3 ± 6.4 | 12.2 ± 5.3 | 1.0 (0.2; 1.9) | 8.5 (1.6; 15.4)
| | | Pelvic muscle contraction: duration(seconds) | 11.7 ± 3.7 | 5.9 ± 1.7 | 2.0 (1.0; 3.0) | 33.7 (17.2; 50.1)
| | | Pelvic muscle contraction: Index computed as average pressure multiplied by duration. | 222.9 ± 126.7 | 71.5 ± 26.4 | 1.6 (0.7; 2.5) | 2.3 (1.0; 3.5)
Bergman, 1987 ^495^ | Bladder training - scheduled clamping and unclamping of the suprapubic Bonnano catheter throughout postoperative period | Nonbladder training - continuous bladder drainage with suprapubic Bonnano catheter throughout postoperative period | Length of postoperative bladder catheterization in days after Burch retropubic urethropexy | 3.3 ± 1.1 | 3.2 ± 1.4 | 0.1 (-0.3; 0.5) | 2.5 (-10.5; 15.5)
N = 89 | | | Length of postoperative bladder catheterization in days after Pereyra procedure | 3.8 ± 1.2 | 3.6 ± 1.7 | 0.1 (-0.3; 0.6) | 3.8 (-7.8; 15.3)
Theofrastous, 2002 ^492^ | Pelvic floor muscle training: 4 office biofeedback sessions and home exercise | Bladder training | Vaginal pressure: mean sustained contraction | 16.7 ± 12.9 | 13.1 ± 10.6 | 0.3 (0.0; 0.6) | 2.3 (-0.2; 4.9)
N = 137 | | | Vaginal pressure: mean fast contraction | 22.3 ± 16.2 | 18.3 ± 14.0 | 0.3 (-0.1; 0.6) | 1.4 (-0.4; 3.3)
Fantl, 1991 ^503^ | Bladder training using 6 weekly visits included patient education; voiding schedule to have micturition from every 30–60 minutes to every 2.5–3 hours; and positive reinforcement. | Usual care | Urinary loss, g | 17.0 ± 36.0 | 47.0 ± 87.0 | -0.4 (-0.8; -0.1) | -1.0 (-1.7; -0.2)
N = 131
Aukee, 2004 ^494^ | Pelvic floor training by physiotherapist 5 times/12 weeks with home biofeedback | Home program with verbal and written instructions for home practice | Pelvic floor muscle activity while supine (mV) at 12 weeks | 15.1 ± 7.7 | 23.9 ± 7.9 | -1.1 (-1.8; -0.4) | -4.7 (-7.7; -1.7)
N = 35 | | | Pelvic floor muscle activity while supine (mV) at 1 year | 24.7 ± 9.1 | 23.8 ± 8.6 | 0.1 (-0.6; 0.8) | 0.4 (-2.4; 3.2)
Goode, 2003 ^490^ | Behavioral training (biofeedback-assisted pelvic floor muscle training, home exercises, bladder control strategies, and self-monitoring with bladder diaries) and pelvic floor electrical stimulation | Self administered behavioral training administered with a self-help booklet | Bladder capacity in ml (cystometry) | 370.4 ± 143.4 | 355.4 ± 115.3 | 0.1 (-0.2; 0.5) | 0.0 (-0.1; 0.1)
N = 200
Bo, 1999 ^513^ | Pelvic floor muscle exercise with 8–12 maximum contractions in 3 series/day and 45 minute/week group sessions | Untreated control group | Change in the strength of pelvic floor muscle | 19.2 ± 10.5 | 16.0 ± 4.2 | 0.4 (-0.1; 0.9) | 2.5 (-0.6; 5.7)
N = 122 | Electrical stimulation using vaginal intermittent stimulation with the MS 106 Twin at 50Hz 30 minutes/day. | Untreated control group offered the use of a continence guard | Change in strength of pelvic floor muscle | 18.6 ± 15.3 | 16.0 ± 4.2 | 0.2 (-0.3; 0.7) | 1.5 (-1.6; 4.5)
| | | Change from baseline in 24 hour pad test (g) | -0.5 ± 21.4 | -7.1 ± 37.8 | 0.2 (-0.3; 0.7) | -3.0 (3.9; -9.9)
| | | Change from baseline in stress pad test (g) | -7.4 ± 34.4 | -12.7 ± 41.8 | 0.1 (-0.4; 0.6) | -1.1 (2.8; -5.0)
| Pelvic floor exercise with 8–12 contractions 3 times/day and in groups with skilled physical therapists 1/week. | Untreated control group offered the use of a continence guard | Change from baseline in stress pad test (g) | -30.2 ± 33.9 | -12.7 ± 41.8 | -0.5 (-1.0; 0.1) | 3.6 (7.6; -0.4)
| | | Change from baseline in 24 hour pad test (g) | -6.6 ± 14.0 | -7.1 ± 37.8 | 0.0 (-0.5; 0.5) | -0.2 (6.8; -7.3)
Cammu, 1998 ^514^ | Weekly session of pelvic floor exercises vaginal probe-EMG biofeedback using perineometer | Vaginal weight cones (20, 32, 45, 57, and 70g) for 15 minutes twice daily | Squeezing capacity-fast (mV) | 10.7 ± 5.9 | 9.0 ± 4.1 | 0.3 (-0.2; 0.8) | 3.7 (-1.9; 9.4)
N = 30 | | | Squeezing capacity-slow (mV) | 11.4 ± 6.2 | 9.7 ± 5.4 | 0.3 (-0.2; 0.8) | 3.0 (-2.2; 8.3)
Sung, 2000 ^524^ | Functional electrical stimulation-biofeedback for 20 minutes/session with frequency 35Hz–50Hz and contractions of 32 seconds, 2 sessions/week | Usual care | Peak pressure, mm/Hg | 41.5 ± 9.8 | 33 ± 7.3 | 1.0 (0.4; 1.5) | 3.0 (1.4; 4.6)
N = 90 | | | Duration of contraction, seconds | 2.3 ± 1.2 | 1.6 ± 0.6 | 0.7 (0.2; 1.3) | 46.1 (13.4; 78.8)
| Intensive pelvic floor muscle exercises | | Duration of contraction, seconds | 2.2 ± 0.5 | 1.6 ± 0.6 | 1.1 (0.5; 1.6) | 67.9 (33.9; 101.9)
| | | Peak pressure, mm/Hg | 38.7 ± 7.8 | 33 ± 7.3 | 0.8 (0.2; 1.3) | 2.3 (0.7; 3.9)
Berghmans, 1996 ^522^ | Pelvic floor muscle exercise with biofeedback with EMG vaginal probe and visual control. | Pelvic floor muscle exercise | Urine loss per 48 hour pad test | 12.2 ± 15.4 | 12.5 ± 12 | 0.0 (-0.6; 0.6) | -0.2 (-5.1; 4.8)
N = 40
Miller, 1998 ^515^ | Immediate intervention group taught intentionally contracting the pelvic floor muscles before and during a cough (Knack ) | Baseline levels | Urine leakage on medium cough paper towel test | 0.4 ± 1.1 | 19.9 ± 36.7 | -0.7 (-1.5; 0.0) | -3.7 (-7.6; 0.2)
N = 27 | | | Urine leakage on deep cough paper towel test | 8.0 ± 18.2 | 29.8 ± 36.2 | -0.8 (-1.5; 0.0) | -2.5 (-5.2; 0.1)
| | Wait-listed control group | Urine leakage on medium cough paper towel test | 0.4 ± 1.0 | 21.2 ± 44.8 | -0.6 (-1.4; 0.1) | -3.0 (-6.7; 0.6)
| | | Urine leakage on deep cough paper towel test from | 5.4 ± 15.3 | 26.8 ± 46.7 | -0.6 (-1.4; 0.2) | -2.3 (-5.1; 0.6)
| | | Areas of wetness (cm/H2O) on paper towel test after medium cough | 0.4 ± 1.1 | 19.8 ± 36.7 | -0.7 (-1.5; 0.0) | -3.7 (-7.7; 0.2)
Liebergall-Wischnitzer, 2005 ^523^ | Pelvic floor muscle exercise 15 minutes with 30 minute session/week | Paula method of circular muscle training 15–45 minutes/day with training sessions of 45 minutes/week | Change from baseline in pelvic muscle strength, cm/H20 | 0.14 ± 3.9 | -0.02 ± 7.4 | 0.0 (-0.5; 0.5)
N = 63 | | | Urine loss per 1 hour pad test | 2.7 ± 7.2 | 3.2 ± 5.8 | -0.1 (-0.6; 0.4) | -2.4 (-17.8; 13.0)
Aukee, 2002 ^521^ | Pelvic floor muscle exercise after verbal and written instructions for home practice of 20 minutes/day 5 times/week and individual EMG assisted biofeedback device with vaginal probe and verbal control. | Pelvic floor muscle exercise after verbal and written instructions for home practice of 20 minutes/day 5 times/week | Pelvic floor muscle activity (mV) Supine | 25.8 ± 10 | 20.1 ± 8.6 | 0.6 (-0.1; 1.3) | 3.0 (-0.6; 6.7)
N = 30 | | | Pelvic floor muscle activity (mV) Standing | 21.4 ± 10.3 | 20.9 ± 8.6 | 0.1 (-0.7; 0.8) | 0.3 (-3.2; 3.7)
| | | 24 hour pad test (g) | 19 ± 19.7 | 22.5 ± 19.6 | -0.2 (-0.9; 0.5) | -0.8 (-4.0; 2.4)
Burns, 1993 ^517^ | Pelvic muscle exercise with 4 sets of 20 increasing by 10/set until maximum 200 sets/day | Usual care | Electromyography | 3.0 ± 3.4 | 3.5 ± 4.4 | -0.1 (-0.6; 0.3) | -3.7 (-16.1; 8.7)
N = 135 | | | Functional urethral length, cm/H20 | 20.0 ± 4.0 | 18.0 ± 6.0 | 0.4 (0.0; 0.8) | 2.2 (-0.2; 4.6)
| | | Maximal urethral pressure, cm/H20 | 31.0 ± 18.0 | 30.0 ± 19.0 | 0.1 (-0.4; 0.5) | 0.2 (-1.3; 1.6)
| Biofeedback using vaginal EMG probe, contraction for 10 seconds and relaxations for 10 seconds 10 times in each weekly session | | Maximal urethral pressure, cm/H20 | 28.0 ± 12.0 | 30.0 ± 19.0 | -0.1 (-0.6; 0.3) | -0.4 (-1.9; 1.1)
| | | Functional urethral length, (cm/H20) | 21.0 ± 6.0 | 18.0 ± 6.0 | 0.5 (0.1; 0.9) | 2.8 (0.3; 5.3)
| | | Electromyography | 4.0 ± 3.1 | 2.0 ± 1.8 | 0.8 (0.3; 1.2) | 39.3 (16.4; 62.2)
Burns, 1990 ^519^ | Kegel Pelvic floor exercises 4 times/day | Usual care | Mean urethral closure pressure | 30.2 ± 14.0 | 28.1 ± 11.0 | 0.2 (-0.3; 0.6) | 0.6 (-1.0; 2.2)
N = 128 | | | Electromyography contractions | 3.0 ± 3.4 | 3.5 ± 4.4 | -0.1 (-0.6; 0.3) | -3.5 (-16.3; 9.2)
| Biofeedback with vaginal EMG probe and visual control | | Mean urethral closure pressure | 28.7 ± 12.2 | 28.1 ± 11.0 | 0.1 (-0.4; 0.5) | 0.2 (-1.4; 1.8)
| | | Electromyography contractions | 6.0 ± 5.1 | 3.5 ± 4.4 | 0.5 (0.1; 1.0) | 14.9 (2.1; 27.6)
Sherman, 1997 ^518^ | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 5 times/session, 20 minutes twice/day with urethral biofeedback using vaginal EMG probe. | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 5 times/session 20 minutes twice/day alone | Bladder capacity | 398.9 ± 104.6 | 331.9 ± 101.7 | 0.6 (0.0; 1.3) | 0.2 (0.0; 0.4)
N = 39 | | | Maximum urethral closure pressure | 80.2 ± 27.5 | 77.2 ± 38.4 | 0.1 (-0.5; 0.7) | 0.1 (-0.7; 0.9)
Aksac, 2003 ^516^ | Pelvic floor muscle exercise (contractions for 10 seconds and relaxation for 20 seconds, 10 times/session, 3 sessions/day) via digital palpation at home | Usual care | 1-hour pad test, g | 2.1 ± 0.4 | 28.2 ± 3.7 | -12.3 (-15.6; -9.0) | -43.6 (-55.3; -31.9)
N = 50 | | | Perineometry, cm/H20 | 37.5 ± 8.7 | 20.0 ± 3.9 | 2.3 (1.4; 3.3) | 11.7 (6.8; 16.5)
| | | Pelvic floor muscle strength via digital palpation | 4.8 ± 0.4 | 3.3 ± 0.6 | 3.2 (2.0; 4.3) | 96.0 (61.9; 130.1)
| Pelvic floor muscle exercise (contractions for 10 sec and relaxation for 20 sec) via biofeedback (vaginal probe in EMG pressure mode) 3 times/week | | 1-hour pad test, g | 1.2 ± 0.2 | 28.2 ± 3.7 | -12.8 (-16.3; -9.4) | -45.5 (-57.7; -33.3)
| | | Perineometry, cm/H20 | 50.0 ± 11.5 | 20.0 ± 3.9 | 3.1 (2.0; 4.2) | 15.4 (9.9; 21.0)
| | | Pelvic floor muscle strength via digital palpation | 4.9 ± 0.2 | 3.3 ± 0.6 | 4.2 (2.9; 5.6) | 128.3 (87.6; 169.0)
Arvonen, 2001 ^527^ | Pelvic floor muscle training program with contractions/relaxations for 5 seconds 10 times 2 times/day | Pelvic floor muscle training program with contractions/relaxations for 20/20 seconds 10 times 2 times/day using weighted vaginal balls 50–100g | Urine Leakage (g) | 5.0 ± 56.7 | 1.0 ± 66.0 | 0.1 (-0.6; 0.7) | 6.5 (-58.0; 71.0)
N = 37 | | | Muscle strength | 3.0 ± 1.3 | 4.0 ± 0.7 | -0.9 (-1.6; -0.3) | -23.6 (-40.6; -6.5)
Wells, 1991 ^520^ | Pelvic muscle exercises with contractions for 10 seconds and relaxation for 10 seconds 90–160 times/day | Phenylpropanol amine hydrochloride in a dose of 50mg/day, increasing to 50mg 2 times/day | Anterior-posterior pelvic muscle strength | 1.5 ± 0.1 | 1.3 ± 0.1 | 2.9 (2.5; 3.4) | 233.0 (197.1; 269.0)
N = 157
Mørkved, 2003 ^486^ | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist. At home, 3 sets of 10 high intensity (close to maximum) contractions per day with a biofeedback apparatus | Pelvic floor muscle training with 3 sets of 10 contractions 3 times/day, individually supervised by a physical therapist At home, 3 sets of 10 high intensity (close to maximum) contractions per day without biofeedback | Change in Pelvic Floor Muscle Strength Measured by Vaginal Squeeze Pressure (cm H2O) | 25.90±14.86 | 25.40±15.15 | 0.03 (-0.35; 0.42)
N - 103
6 months

Bold- significant differences in outcomes at 95% confidence level

Table F97 Effects of behavioral interventions on perceived urinary incontinence in males (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Mathewson-Chapman, 1997 ^534^ | Education booklet and instructions for pelvic muscle exercises with biofeedback: maximal contractions for 10 seconds, slow release and 10 seconds of muscular relaxation, 3 times/week. | Standard care with no pelvic muscle exercises. | Self reported pad use for urinary incontinence | 0.6 ± 1.6 | 1.8 ± 2.7 | -0.5 (-1.1; 0.0) | -30.5 (-61.6; 0.6)
N = 53 | | All patients were recommended to limit coffee, tea, chocolate, alcohol, and over counter medication for bladder control. | Self reported episodes of urinary incontinence | 0.8 ± 2.0 | 1.0 ± 0.3 | -0.1 (-0.7; 0.4) | -10.9 (-66.0; 44.1)
Floratos, 2002 ^535^ | 2-channel electromyographic biofeedback as learning tool for pelvic muscle exercises immediately after catheter removal | Verbal feedback as learning tool for pelvic muscle exercises immediately after catheter removal: sub maximal contractions 3–5 seconds, relaxation for 6–10 seconds, 80–100 times/day | Pad use for urine incontinence, number/day | 0.5 ± 0.1 | 0.8 ± 1.4 | -0.4 (-1.0; 0.3) | -48.5 (-129.3; 32.4)
N = 42
Porru, 2001 ^538^ | Verbal instruction, feedback on contractions of pelvic floor muscles, and verbal reinforcement of appropriate responses to teach selective contractions of anal sphincter muscles and relaxation of abdominal muscles 45 times/day | Standard care without instruction on pelvic floor muscle exercises | Voiding interval, minutes | 118.5 ± 24.0 | 110.0 ± 23.0 | 0.4 (-0.2; 0.9) | 0.3 (-0.1; 0.8)
N = 58

Table F98 Effects of behavioral interventions on pad test in males (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Floratos, 2002 ^535^ | 2-channel electromyographic biofeedback as learning tool for pelvic muscle exercises immediately after catheter removal | Verbal feedback as learning tool for pelvic muscle exercises immediately after catheter removal: sub maximal contractions 3–5 seconds, relaxation for 6–10 seconds, 80–100 times/day. | Urine loss in pad test (g) | 0.5 ± 10.1 | 0.5 ± 0.1 | 0.0 (-0.6; 0.6) | 0.0 (-128.3; 128.3)
N = 42
Moore, 1999 ^533^ | Intensive pelvic muscle exercises conducted by a physiotherapist for 30 minutes 2/week: maximum contractions for 5 seconds, slow release and 10 seconds of muscular relaxation | Standard treatment with verbal and written instructions about postoperative pelvic muscle exercises from urologist and nurses at the pre-admission clinic. | Urine loss in pad test (g) | 69.9 ± 8.7 | 54.1 ± 6.9 | 2.0 (1.2; 2.8) | 3.8 (2.3; 5.2)
N = 63 | | | Urine loss in pad test (g) | 98.2 ± 9.0 | 54.1 ± 6.9 | 5.6 (4.2; 7.0) | 10.3 (7.7; 12.8)
Mathewson-Chapman, 1997 ^534^ | Education booklet and instructions for pelvic muscle exercises with biofeedback: maximum contractions for 10 seconds, slow release and 10 seconds of muscular relaxation 3 times/week. | Standard care with no pelvic muscle exercises. All patients were recommended to limit coffee, tea, chocolate, alcohol, and over counter medication for bladder control. | Urine loss in pad test (g) | 1.0 ± 1.0 | 14.2 ± 48.2 | -0.4 (-1.0; 0.2) | -2.8 (-6.7; 1.1)
N = 53
Paterson, 1997 ^545^ | Urethral milking after appropriate education | Counseling including drinking pattern, aperient use, toileting habits, dietary advice, and relaxation therapy. | Improvement in pad weight gain (g) | 4.0 ± 8.0 | 0.0 ± 4.0 | 0.6 (-0.1; 1.4)
N = 49 | Pelvic muscle exercise with 1 second contractions (~5) to increase length and strengths of contractions as much as possible. | | | 4.3 ± 8.9 | 0.0 ± 4.0 | 0.6 (-0.1; 1.4)

Bold- significant differences in outcomes at 95% confidence level

Table F99 Effects of behavioral interventions on perceived urinary incontinence in males and females from the community (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control 95% CI)
Sample
McDowell, 1999 ^543^ | Biofeedback-assisted pelvic floor muscle training by nurse practitioners skilled in behavioral therapies for urinary incontinence | Usual care with attention control | Urinary incontinence episodes/day | 1.8 ± 2.9 | 3.5 ± 3.0 | -0.6 (-1.0; -0.2) | -16.5 (-27.6; -5.3)
N = 105
90% female
Engberg, 2002 ^544^ | Prompted voiding by caregivers to approach subjects hourly for perceived wet/dry status vs. objective wet checks, feedback and praising for correct response, toilet by request, positive feedback for appropriate toileting. | Usual care with attention control | Percent reduction in all incontinent episodes/day | 47.0 ± 39.2 | 27.2 ± 26.1 | 0.6 (-0.3; 1.5) | 2.2 (-1.2; 5.6)
N = 19 | | | Percent decrease in daytime incontinent episodes/day | 50.1 ± 41.3 | 37.3 ± 34.3 | 0.3 (-0.6; 1.2) | 0.9 (-1.5; 3.3)
68% female | | | Reduction in day and night % wet | 40.6 ± 44.3 | 23.0 ± 22.7 | 0.5 (-0.4; 1.4) | 2.2 (-1.8; 6.2)

Bold- significant differences in outcomes at 95% confidence level

Table F100 Electrical stimulation on risk and progression of urinary incontinence in adults

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Electrical stimulation of pelvic floor muscles
But, 2003 ^546^ | 55 women with urinary incontinence older than 18 years, not pregnant, and not physically or mentally disabled. | 1 Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz.; 2 Placebo treatment with sham not active device. | Pad test use and pad weight. Self reported nocturia. PFM contractions measured with perineometer after performing five maximal consecutive PFM contractions, with an interval of 30 seconds between every two contractions. The power of the PFM contractions was measured as the percentage of the maximum (100% = 45mm/Hg); the time of the PFM contractions was measured in seconds. | No intention to treat. Double-blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
Placebo controlled | Exclusion criteria: Implanted electronic equipment (pacemakers), urolithiasis, bladder infection, tumor, recent urethral or continence surgery, use of anticholinergic drugs, beta-blocking agents, and diuretics.
RCT to examine the effects of functional magnetic stimulation in the treatment of women with urinary incontinence. | Loss of followup: 7.7%
Duration: 2 months
Spruijt, 2003 ^547^ | 51 women ≥65 years of age, with symptoms of stress, urge or mixed urinary incontinence of >3 months' duration, and with urinary leakage >10cc/24hours. Exclusion criteria: Persistent urinary tract infection (positive urine culture after antibiotic treatment), recurrent urinary tract infection (within 4 weeks after treatment), bladder pathology or dysfunction because of fistula, tumor, pelvic irradiation, neurological or other chronic conditions (diabetes mellitus, Parkinson's disease), genital, pacemaker, and insufficient mental condition. | 1 Intravaginal electrical stimulation of the pelvic floor using stimulator generated biphasic current pulses with duration of 1ms and a frequency of 50Hz (stress urinary incontinence) or 20Hz (urge urinary incontinence).; 2 Kegel exercise program with verbal instructions on how to exercise at home. | Urinary leakage during a pad test, pelvic muscle strength measured by a perineometer, detrusor instability. Self reported change in urinary symptoms based on the PRAFAB score. | No intention to treat. Open label. Blocked randomization (Pocock).
RCT to examine the effects of intravaginal electrical stimulation of the pelvic floor for urinary incontinence in elderly women. | Loss of followup: 3.9% | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
Duration: 8 weeks
Yamanishi, 2000 ^548^ | 68 patients with urinary incontinence due to detrusor overactivity urodynamically defined as involuntary detrusor contractions of more than 15cm/H2O during the filling phase. | 1 Electrical stimulation 15 minutes twice daily for 4 weeks (vaginal electrode in women and an anal or surface electrode in men to provide alternating pulses of 10Hz square waves of 1-ms pulse duration and a maximum output current of 60mA).; 2 Sham inactive device | Self reported urinary incontinence in frequency/volume chart and urodynamic outcomes. Degree of urgency scored as 0-none, 1-slight, 2-moderate, and 3-very much. | No intention to treat. Double-blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Placebo controlled | Exclusion criteria: Use of anticholinergics or tricyclic depressants, pelvic floor exercise, bladder training, or pelvic surgery before entry into the study. | | | Sample size not justified.
RCT to examine effects of electrical stimulation for urinary incontinence due to detrusor overactivity. | Loss of followup: 11.8%
Duration: 4 weeks
Yamanishi, 2000 ^549^ | 32 patients with urinary incontinence due to detrusor overactivity defined urodynamically as involuntary detrusor contractions of more than 15cm/H2O during the filling phase. | 1 Functional magnetic stimulation applied continuously at 10Hz; 2 Functional electrical stimulation applied continuously at 10Hz with vaginal electrode in women and a surface electrode on the dorsal part of the penis in men. | Urodynamic outcomes before and after stimulation. | No intention to treat. Open label. Randomization not reported. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
RCT to examine effects of functional magnetic stimulation and functional electrical stimulation on the inhibition of detrusor overactivity. | Exclusion criteria: Not reported | | | Sample size not justified.
Duration: acute | Loss of followup: No followup
Lappin, 2003 ^550^ | 145 patients 18–65 years old with clinically definite multiple sclerosis and light spasticity (>2 in 6 point scale) and bladder control problems. | 1 Daily simulation with low frequency pulsed electromagnetic fields; 2 Sham inactive device | The MS Quality of Life Inventory (MSQLI) was used to assess changes in bladder control form 0-none to 10-severe | No intention to treat. Double-blind. Central computer generated randomization.
Crossover, placebo controlled | Exclusion criteria: Changes in medication last 2 months, pregnancy, pacemaker, chronic diseases. | | | Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
RCT to examine effects of pulsed electromagnetic fields on bladder control in patients with multiple sclerosis. | Loss of followup: 19% | | | Sample size not justified.
Duration: 10 weeks, 2 weeks washout period.
Amaro, 2006 ^551^ | 40 women with predominant urge urinary incontinence. | 1 Effective and sham intravaginal electrical stimulation with 3 20-minute sessions/week using Dualpex Uro 996 frequency of 4Hz.; 2 Sham intravaginal electrical stimulation. | Self reported | Double blind.
RCT to examine the effects of intravaginal electrical stimulation in treating mixed urinary incontinence. | Exclusion criteria: Use of anticholinergic and tricyclic antidepressants, pelvic floor exercise, bladder training, vaginal prolapse >II grade, urinary infection, metal implants, neurological diseases. | | Improvement in urge incontinence | Randomization and allocation concealment unclear. Baseline data confirmed adequacy of randomization.
Duration: 7 weeks, Followup: 1 month | Loss of followup: none | | | Sample size justified.
Berghmans, 2002 ^552^ | 98 patients older than 18 years with proven bladder overactivity defined as Detrusor Activity Index (DAI) ≥0.50, able to understand Dutch. | 1 Pelvic floor exercises with contractions for >20 seconds controlled by physiotherapist palpation with relaxation period of 10 seconds. Bladder training to inhibit the sensation of urgency and to postpone voiding, voiding schedule with an interval >2 hours, positive reinforcement of patient motivation by the physical therapist.; 2 Office- and home-based functional electrostimulation maximum 100mA frequency 4 – 10Hz.; 3 Office-based functional electrostimulation, pelvic floor exercise, and bladder training.; 4 No treatment. All treated subjects received 9 sessions, 1/week | Detrusor Activity Index - combined cystometry outcomes (number of contractions/hour, mean duration of a contraction and mean amplitude of a contraction) and voiding diary (mean volume drunk/hour, mean number of micturitions/hour and mean volume voided per micturition. The DAI represents a score between 0 and 1, where ‘0’ represents no activity of the bladder during the filling phase and ‘1’ represents severe overactivity of the bladder. | Intention to treat.
RCT to examine effects of physiotherapy in women with proven bladder overactivity. | Exclusion criteria: Mechanical intravesical obstruction, urinary calculus, urinary tract infection, colpitis, pacemaker, pregnancy, physiotherapy within 3 months, uncontrolled diabetes mellitus. | | | Single blind.
Duration: 9 weeks | Loss of followup: 8%. | | | Randomization using blocks of 4.
| | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Pages, 2001 ^553^ | 51 women, referred by gynecologists for nonoperative treatment of genuine stress incontinence of mild-to-moderate severity. | 1 Specific physical therapy program. Group therapy 5 times/week and home pelvic floor exercise with 50 contractions for 10 minutes 2times/day. Recommendation of weight loss and aerobic sports.; 2 Biofeedback training daily 90 minutes in groups and individually for 15 minutes, 5 times/week. Intra vaginal pressure sensor and visual biofeedback in computer monitor. | Nocturnal urinary frequency and subjective improvement of incontinence, standardized exams of digital contraction strength, speculum tests, and manometric outcomes. | No intention to treat. Open label.
RCT to examine the effects of intensive group physical therapy program with individual biofeedback training for female patients with urinary stress incontinence. | Exclusion criteria: Not reported. | | | Randomization and allocation concealment unclear. Baseline data not reported.
Duration: 4 weeks | Loss of followup: 21% | | | Sample size not justified.
Sand, 1995 ^554^ | 52 community dwelling women with urodynamically proven genuine stress incontinence, who would comply with visits, not use/seek other treatment for incontinence. | 1 Active pelvic floor stimulator with gradually adjusted 60–80mA from 5 seconds on/1 second off for 15 minutes to 5 seconds on/5 seconds off for 30 minutes.; 2 Sham inactive device. | Self reported urinary stress incontinence and voiding in diaries, urodynamic outcomes, pad test, and pelvic muscle strength. | Intention to treat.
Placebo-controlled | Exclusion criteria: Detrusor instability, pregnancy, pacemaker, prior pelvic floor stimulation, pelvic implanted devices, active vaginal lesions or infections, urinary tract infection, hypermenorrhea or menorrhaghia, urinary retention (>100ml), pelvic surgery in past 6 months, atrophic vaginitis, genital prolapse to introitus, pelvic irradiation, intrinsic sphincteric deficiency. | | | Double-blind.
RCT to examine the effects of transvaginal electrical stimulation in treating genuine stress incontinence. | Loss of followup: 15% | | | Computer-generated random numbers with blocks at a 2:1 rate favoring active over placebo devices.
Duration: 15-weeks | | | | Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Indrekvam, 2001 ^555^ | 3,198 women treated with home-managed electrical stimulation in Norway from 1992-1994. | Home-managed electrical stimulation with vaginal/anal stimulators (20–50Hz) for 6–8 hours/day for at least 3 months before evaluation of the effect. | Self reported frequency of incontinence episodes and amount of leakage before and after treatment, number of voidings during the day and night, and number of protective pads used (4 item ordinal scale). | Intention to treat.
Prospective cohort study to examine the effectiveness of home-managed electrical stimulation on urinary incontinence in females. | Exclusion criteria: Pregnancy, use of a pacemaker, malignancy. | Before-after comparison. | | Not random sampling adjustment for age, duration of incontinence, diagnosis (urge/stress component), previous surgery for urinary incontinence, urodynamic investigation, type of stimulator, frequency, amount of leakage, physicians' work, patients' practical problems and discomfort with treatment.
Duration: 2 years | Loss of followup: 1.2%; 15 women did not start treatment because of severe illness or because they had died, and 24 did not complete the treatment because of pregnancy or cancer. | The stimulators Vitacon Norway AS for long-term stimulation (20–50 Hz) delivered below the sensory threshold.
| | Devices were used for 6–8 hours/day for at least 3 months before evaluation of the effect.
| | Max stimulation (10– 20 Hz) used a high-intensity stimulus. The companies recommended application of not more than 20 min (the machine switches off automatically) daily or at least twice weekly. Patients were advised to increase the stimulation intensity continuously using a control knob to as high as possible, but below the level of pain. The stimulator should be used at least 10–20 times before evaluation of the effect.
Amaro, 2006 ^551^ | 40 women symptoms of predominant urge incontinence not taking anticholinergics or tricyclic antidepressants. | 1 Effective intravaginal electrical stimulation using frequency of 4 Hz with 3 20-minute sessions/week; 2 Sham intravaginal electrical stimulation using frequency of 4Hz with 3 20-minute sessions/week | Self reported urge urinary incontinence. | Intention to treat not stated. Double-blind.
RCT to examine the effects of intravaginal electrical stimulation in mixed urinary incontinence. | Exclusion criteria: Use of pelvic floor exercises or bladder training, vaginal prolapse >grade II, retention complaint or obstruction diagnosis during UDS, urinary infection, changes in cutaneous sensitivity, metal implants, and neurological diseases. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: 7 weeks, Followup: 4 weeks. | Loss of followup: Not reported | | | Sample size justified.
Smith, 1996 ^556^ | 57 women with urinary incontinence. | 18 women with stress urinary incontinence:; 1 Electrical stimulation using frequency 12.5Hz.–50Hz and amplitude 5–10mA–80mA for 15 to 60 minutes 2/day; 2 Kegel exercise 38 women with detrusor instability:; 1 Anticholinergic therapy with Propantheline bromide in dose of 7.5 to 45mg 2–3 times/day; 2 Electrical stimulation using frequency 12.5Hz.–50Hz and amplitude 5–25mA for 15–60 minutes 2/day. | Self reported cure from urinary incontinence and no longer requiring pads. Reduction in episodes of urinary incontinence by >50 and 10 or fewer voids per 24 hours | Intention to treat not stated. Open label.
RCT to examine the effects of intravaginal electrical stimulation on genuine stress urinary incontinence and detrusor instability in women. | Exclusion criteria: Type 3 stress urinary incontinence, pregnancy, urinary retention, vaginal prolapse, cardiac pacemaker, mixed incontinence with no major and minor components. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: 4 months | Loss of followup: 1.8% | | | Sample size not justified.
Brubaker, 1997 ^557^ | 121 women >25 years of age with either urinary incontinence due to detrusor instability or genuine stress incontinence, or both (mixed incontinence) diagnosed with filling urethrocystometry. | 1 The transvaginal electric stimulation for 20 minutes 2 times/day using frequency of 20Hz, a 2-second-4-second work-rest cycle with a range of stimulation intensities, from 0–100mA; 2 Sham inactive device | Multichannel urodynamic testing, quality-of-life scale, and urinary diaries | No intention to treat. Double-blind.
RCT to examine the effects of transvaginal electrical stimulation for treatment of urinary incontinence in women. | Exclusion criteria: Urinary incontinence other than genuine stress incontinence, detrusor instability, or mixed incontinence; leakage episodes <3/week, inadequate genitourinary estrogen (minimum 3 months HRT), inadequate cognitive ability (investigator judgment), urinary tract infection, anatomic defect that precluded use of device, postvoid residual >100ml, implanted electric device, genitourinary surgery, drug treatment for urinary incontinence, anticipated geographic relocation during study. | | | Computer generated randomization stratified by incontinence type.
Duration: 8 weeks, Followup: 2 weeks | Loss of followup: 18%. | | | Allocation concealment unclear but centralized data manager blinded for treatment status analyzed the data.
| | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Amaro, 2005 ^558^ | 40 women with mixed urinary incontinence and predominant urge incontinence. | 1 Intravaginal electrical stimulation with 3 20-minute sessions/week using 4Hz frequency.; 2 Sham stimulation with inactive device | Objective evaluation of perineal muscle by perineometry, vaginal weight test, and urodynamic outcomes | No intention to treat. Double-blind.
RCT to examine the effect of intravaginal electrical stimulation on pelvic floor muscle strength in women with mixed urinary incontinence. | Exclusion criteria: Anticholinergic and tricyclic antidepressant medications, pelvic floor exercise, bladder training, vaginal prolapse more than II grade, urinary tract infection, metal implants, and neurological diseases. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: 1 month | | | | Sample size justified.
But, 2005 ^559^ | 39 women with mixed urinary incontinence and predominant urge incontinence. | 1 Functional magnetic stimulation applied continuously at 18.5Hz day and night; 2 Sham inactive device | Urodynamic diagnosis of detrusor overactivity and patient subjective assessment of mixed urinary incontinence. | No intention to treat. Double blind.
RCT to examine effects of functional magnetic stimulation for treating women with mixed urinary incontinence. | Exclusion criteria: Not reported. | | | Randomization and allocation concealment not reported. Baseline data not reported.
Duration: 2 months | Loss of followup: Not reported | | | Sample size not justified.
Bo, 1997 ^560^ | 12 women with genuine stress incontinence participated in pelvic floor exercise program with 8–12 contractions. | 3 voluntary PFM contractions and 2 electrical stimulators | Urethral and bladder pressures | No intention to treat. Open label.
Crossover RCT to examine the effect of voluntary pelvic floor muscle contraction and vaginal electrical stimulation on urethral pressure in women with genuine stress incontinence. | Exclusion criteria: Not reported | 1 Conmax 50Hz - pulse width 0.75ms, 0–90mA; 2 Medicon 50Hz - pulse width 0.5ms, 0–100mA | | Randomization and allocation concealment not reported. Baseline data is not reported. Sample size not justified.
Duration: 1 day experiment. | Loss of followup: Not applicable
Luber, 1997 ^561^ | 57 women with stress urinary incontinence who could adequately retain the vaginal probe and cooperate with the study protocol. | 1 Functional electrical stimulation with 15-minute treatment session/day using pulse-width of 2msec scheduled for 2 seconds with 4 seconds rest, frequency of 50Hz, and power 10–100mA.; 2 Sham stimulation with inactive device. | Self reported improvement or cure from stress urinary incontinence and urodynamic outcomes. | Double-blind.
RCT to examine the effects of functional electrical stimulation for stress incontinence in women. | Exclusion criteria: Significant pelvic prolapse and detrusor instability, postvoid residual urine >100cc, extra urethral incontinence, history of vaginal intraepithelial neoplasia, urinary tract infection, a fixed, immobile urethra, and urodynamic evidence consistent with intrinsic sphincteric deficiency. | | Objective cure: negative stress test on repeat urodynamics. Objective failure: positive stress test on repeat studies. | Randomization using the table of random numbers.
Duration: 3 months | Loss of followup: 18.5% | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Emmons, 2005 ^562^ | 85 women older than 18 years, with symptoms of overactive bladder with urge incontinence,>8 voids per day, subjective urgency to void, and urge-associated incontinence at least twice during a 3-day period of time. | 1 Acupuncture treatment expected to improve bladder symptoms; 2 Placebo acupuncture treatment designed to promote relaxation | Number of incontinent episodes over 3 days, voiding frequency and urgency, cystometric bladder capacity, maximum voided volume, and the urinary distress inventory and incontinence impact questionnaire symptom scores. | No intention to treat. Single-blind.
RCT to examine the effects of acupuncture on overactive bladder in women. | Exclusion criteria: Pregnancy, taking medications for overactive bladder or receiving acupuncture treatments for any condition, unable to ambulate or unable to complete a 3-day voiding diary, and hematuria or untreated urinary tract infection. | | | Computer-generated randomization with random numbers table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
Duration: 4 weeks | Loss of followup: 13% | | | Sample size justified.
Yamanishi, 1997 ^563^ | 35 patients with stress incontinence. | 1 Electrical pelvic stimulation with 50Hz. square waves of 1msec. pulse duration and vaginal electrode in women and an anal electrode in men for 15 minutes 2 or 3 times daily; 2 Sham electrical pelvic stimulation with inactive device | Frequency/volume chart, results of 1-hour pad test and urodynamic parameters. Subjective data (patient impressions) ranked as very good, good, fair, or not good. Daily frequency of pad changes was scored as 0-no change, 1-once, 2-twice and 3–3 times or more. Degree of disturbance in daily activities was scored as 0-not disturbed, 1-slightly disturbed, 2-moderately disturbed and 3-very disturbed. | No Intention-to-treat. Double-blind (doctors and patients).
CT to examine the effects of electrical pelvic stimulation in stress incontinence. | Exclusion criteria: Persistent urinary infection, uterine or rectal prolapse and cystocele, severe cardiac or cerebrovascular disorders including on-demand heart pacemakers, hepatic disorders and renal dysfunction. | | Cured-no incontinence on the frequency/volume chart and leakage of <1.0gm in the pad test. | Randomization and allocation concealment not reported. Unclear who assigned patients to the treatment groups.
Duration: 4 weeks | Anticholinergics, calcium antagonists, alpha or beta agonists or antagonists, or tricyclic depressants were discontinued medications for 1 week. | | Improved-frequency of incontinence decreased by >50% or if the pad test showed a decrease in leakage by >50%, Unchanged or aggravated-frequency of incontinence or amount of leakage in pad test was unchanged or aggravated | Baseline data confirmed no differences among groups. Sample size not justified.
| Loss of followup: 5.7%
Barroso, 2004 ^564^ | 36 women (24 patients and 12 controls) with stress, urge, or mixed urinary incontinence. | 1 Transvaginal electrical stimulation at home twice a day (20-minute sessions) with frequency of 20 (urge) or 50Hz (stress UI), a pulse width of 300ms, with asymmetrical biphasic pulses, an adjustable current intensity (0–100mA), a 1 s rise time, sustained for 5 seconds and resting for 5 seconds.; 2 Placebo (identical equipment but with no electrical current) | Self reported urinary incontinence in voiding diary. Urodynamic outcomes | No intention to treat. Double-blind.
Placebo controlled | Exclusion criteria: Prolapse or first degree urogenital prolapse, intrinsic sphincter deficiency, cardiac pacemaker; pregnancy, postmenopausal climacteric with symptoms and signs of urogenital atrophy (they could be included after 3 months of treatment with hormone-replacement therapy); urinary tract infection, genitourinary surgery during the previous 6 months; previous electrical stimulation of the pelvic floor; use medication chronically (e.g., antidepressants, diuretics and others) known to possibly change voiding function, reflex urinary incontinence (clear presence of neurological lesions); paradoxical urinary incontinence (presence of intravesical obstructive factor); urinary incontinence caused by overflow, characterized by the presence of a large urinary residual volume; urge incontinence treated with medication during the last 3 months. | | | Randomization before the study by drawing lots.
RCT to examine the effects of transvaginal electrical stimulation on urinary incontinence. | Loss of followup: Not reported | | | Allocation concealment not reported. Baseline data did not confirm adequacy of randomization.
Duration: 12 weeks. | | | | Sample size justified.
Duration of followup: 6 months
Neurostimulation
Scheepens, 2002 ^565^ | 33 patients with chronic voiding dysfunction (urge incontinence with or without urodynamic instabilities), complete urinary retention and incomplete voiding with residual of >100ml. | 1 Bilateral sacral stimulation with external stimulation device to deliver alternating pulses left and right programmed individually at amplitude just above sensory threshold. Patients were instructed to adjust the stimulation amplitude if necessary.; 2 Unilateral sacral stimulation with external stimulation device in a side with the best response using the lowest amplitude | Standardized voiding diaries were used to record voiding, catheterization and leaking episodes | No intention to treat, but all subjects were analyzed. Open label.
Crossover RCT to examine the effects of bilateral sacral neuromodulation. | Exclusion criteria: Stress incontinence, untreated urinary tract infection, stone disease, psychiatric disturbance, pregnancy, neurogenic voiding disorders (including diabetes mellitus, spinal cord injury, multiple sclerosis), Reiter's syndrome, pelvic pain syndrome, cerebrovascular accident less than 6 months ago, anatomical obstructive voiding disorders, malignancy of the urinary tract, severe (grade III/IV) pelvic prolapse, cystocele, urethrocele, enterocele, proven interstitial cystitis or evident functional neurological asymmetry. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: 4 days | Loss of followup: none | | | Sample size justified.
Schmidt, 1999 ^566^ | 98 patients older than 16 years refractory to standard medical therapy, with 100ml bladder capacity and normal upper urinary tract, able to complete study documentation and return for followup evaluation. | 1 Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place.; 2 Standard medical therapy | Voiding diary results and pad test. | No intention to treat. Open label.
RCT to examine the effects of sacral nerve stimulation for treatment of refractory urinary urge incontinence. | Exclusion criteria: Neurological conditions (multiple sclerosis, diabetes with peripheral nerve involvement, spinal cord injury, stroke), stress urinary incontinence, primary pelvic pain | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: 5 months | Loss of followup: 22% | | | Sample size not justified.
Weil, 2000 ^567^ | 44 patients >16 years with refractory urge incontinence, normal urinary tract function, muscular and sensory responsiveness, detrusor storage capacity >100ml and no sphincter anomaly. | 1 Sacral root neuromodulation with an implantable impulse generator; 2 Prior conservative management: medications, or pelvic floor exercise | Self reported urge urinary incontinence, voiding diaries, quality of life questionnaires, urodynamic testing | No intention to treat. Open label.
RCT to examine effects of sacral root neuromodulation refractory urinary urge incontinence. | Exclusion criteria: Stress urinary incontinence, multiple sclerosis, Reiter's syndrome, uncontrolled diabetes, pregnancy, spinal cord injury or cerebrovascular accident, active degenerative disc diseases, bleeding complications, urinary tract infection. | | | Computer generated randomization, 1:1 ratio. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
Duration: 6 months. | Loss of followup: 4.5% | | | Sample size not justified.
Karademir, 2005 ^568^ | 43 patients with symptoms of detrusor overactivity confirmed urodynamically. | 1 Stoller afferent neurostimulation with frequency 20Hz and amplitude 0.5–10mA; 2 Stoller afferent neurostimulation with frequency 20Hz and amplitude 0.5–10mA combined with 5mg of oral oxybutynin hydrochloride | Self reported quality of life and voiding diaries | Intention to treat not stated.
RCT to examine the effects of Stoller afferent neurostimulation with and without a low-dose anticholinergic (oxybutynin hydrochloride) in patients with detrusor overactivity. | Exclusion criteria: Urinary tract obstruction, urinary retention, neurologic or metabolic disorder, other treatments for urinary incontinence. | | | Randomization and allocation concealment not reported. Baseline data reported for age only. Sample size not justified.
Duration: 8 weeks | Loss of followup: Not reported
Bower, 1998 ^569^ | 48 women with proved detrusor instability or sensory urgency. | 1 Active transcutaneous electrical nerve stimulation with 10Hz. frequency and 200 microsecond pulse width (sacral placement).; 2 Active transcutaneous electrical nerve stimulation with 150Hz. frequency and 200 microsecond pulse with (suprapubic placement); 3 Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement. | Urodynamic outcomes. | No intention to treat. Double blind.
RCT to examine the effects of surface neuromodulation on cystometric pressure and volume parameters in women with detrusor instability or sensory urgency. | Exclusion criteria: Urinary tract infection, pregnancy, cardiac pacemaker, impaired cognition, neurogenic bladder dysfunction or cystocele beyond the introitus. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: unclear | Loss of followup: Not reported | | | Sample size justified.
Fujishiro, 2000 ^570^ | 62 women, 37 to 79 years old with stress incontinence, >1 episodes of urinary leakage recorded in a 3-day voiding diary, and 2gm or more urine loss on a 1-hour pad test. | 1 Magnetic stimulation of sacral roots with 15Hz. frequency, 50% intensity output for 5 seconds per minute for 30 minutes.; 2 Sham stimulation with inactive device | Self reported number of voids daily, mean urine volume per void, and number of leaks for 3 days | No intention to treat. Open label.
RCT to examine the effects of magnetic stimulation of the sacral roots for the treatment of stress incontinence. | Exclusion criteria: Urinary infection, interstitial cystitis and large uterine myoma, and other treatments for stress incontinence, including pelvic floor exercises, medical treatment and electrical stimulation. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: 1 week | Loss of followup: Not reported | | | Sample size not justified.
Fujishiro, 2002 ^571^ | 37 women 43 to 75 years old with the complaint of urinary frequency and/or urge incontinence, >8 voids daily and/or >1 episode of urge incontinence on a 3-day voiding diary, and mean of less than 250ml. urine volume per void on a 3-day voiding diary. | 1 Magnetic stimulation of sacral roots with 15Hz. frequency, 50% intensity output for 5 seconds per minute for 30 minutes.; 2 Sham stimulation with inactive device | Self reported number of voids daily, mean urine volume per void, and number of leaks for 3 days. | No intention to treat. Open label.
RCT to examine the effects of magnetic stimulation of the sacral roots for treating urinary frequency and urge incontinence. | Exclusion criteria: neurological disorders suggesting neurogenic bladder dysfunction, apparent episode of stress incontinence, urinary infection, interstitial cystitis or large uterine myoma, other treatments for urinary frequency or urge incontinence, including pelvic floor exercises, medical treatment or electrical stimulation. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration 1 week | Loss of followup: not reported | | | Sample size not justified.
Walsh, 2001 ^572^ | 146 patients with urge incontinence refractory to an average of three previous treatments, encompassing bladder retraining, anticholinergic medication, or bladder/urethral dilatation. | 1 Antidromic transcutaneous sacral neurostimulation during the second fill of standard urodynamic filling cystometry with 10Hz frequency, a pulse width of 200msec in continuous mode at the maximum tolerable level.; 2 Control group underwent a second fill of standard urodynamic filling cystometry without neurostimulation | Cystometric filling volumes and corresponding detrusor pressures at first desire to void, strong desire to void, sensation of urgency, and maximum cystometric capacity | Intention to treat nor stated. Open label.
RCT to examine the effects of noninvasive third sacral nerve (S3) stimulation on bladder activity during filling cystometry. | Exclusion criteria: Not reported. | | | Randomization in age- and gender-matched control and study groups. Allocation concealment not reported.
Duration: Acute experiment | Loss of followup: Not applicable | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Borawski, 2007 ^573^ | 30 women >55 years with refractory urge incontinence after failure of medical, behavioral, and pelvic floor reeducation management. | 1 Electrical stimulation with percutaneous needle electrode (22-G spinal needle) placement; 2 Electrical stimulation with surgical first stage lead placement | Self reported urinary incontinence in bladder diary, daily pad count, and a 24-hour pad weight test. Successful test stimulation period for implantation of the impulse generator->50% improvement in daily incontinence episodes or 24-hour pad weight. | No Intention to treat. Open label.
RCT to examine the effects of percutaneous needle electrode technique or a surgical first stage lead placement on implantation of a pulse generator in older urge incontinent women. | Exclusion criteria: Not reported. | | | Randomization and allocation concealment not reported. Baseline data did not confirm adequacy of randomization.
Duration: 2 weeks | Loss of followup: 6.6% | | | Sample size justified.

Table F101 Effects of physiotherapy on urinary continence in females (events) (table sorted by rate of continence after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Definition of Continence | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
But, 2003 ^546^ | Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz | Placebo treatment with sham not active device | Success of treatment of urge urinary incontinence | 24 | 5 | 79.0 | 22.0 | 3.5 (1.6; 7.8) | 2 (1;8) | 570 (131; 1,488)E
N = 52 | Functional magnetic stimulation applied continuously at 18.5Hz day and night | Sham inactive device | Cured form Detrusor over activity | 17 | 11 | 75.0 | 66.6 | 1.1 (0.7; 1.6)
| Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz | Placebo treatment with sham not active device | No urge incontinence (cured) | 12 | 0 | 40.0 | 1.0 | 18.5 (1.2; 297.4) | 3 (0;638) | 390 (2; 2,964)E
Smith, 1996 ^556^ | Electrical stimulation using frequency 12.5Hz. –50Hz and amplitude 5–10mA–80mA for 15 to 60 minutes 2/day | Kegel exercise | Cured for incontinence | 2 | 1 | 22.0 | 11.0 | 2.0 (0.2; 18.3)
N = 57 | | | Improved urinary incontinence | 4 | 1 | 22.0 | 11.0 | 1.8 (0.2; 13.9)
Pages, 2001 ^553^ | Specific physical therapy program. | Biofeedback training 90 minutes/day in group and individually for 15 minutes, 5 times/week Intra vaginal pressure sensor and visual biofeedback in computer monitor | No stress urinary incontinence episodes and symptoms | 6 | 4 | 22.0 | 28.0 | 0.7 (0.2; 2.1)
N = 51 | Group therapy 5 times/week and home pelvic floor exercise with 50 contractions for 10 minutes 2 times/day.
| Recommendation of weight loss and aerobic sport
Sand, 1995 ^554^ | Active pelvic floor stimulator with gradually adjusted 60–80mA from 5 seconds on/1 sec off for 15 minutes to 5 seconds on/5 seconds off for 30 minutes | Sham inactive device. | Cured from stress urinary incontinence | 7 | 2 | 20.0 | 12.0 | 1.7 (0.4; 7.3)
N = 52
Smith, 1996 ^556^ | Anticholinergic therapy with Propantheline bromide in dose of 7.5 to 45mg 2–3 times/day | Electrical stimulation using frequency 12.5Hz. –50Hz and amplitude 5–25mA for 15–60 minutes 2/day | Cured for incontinence | 3 | 4 | 16.7 | 11.0 | 0.4 (0.1; 1.3)
N = 57
Luber, 1997 ^561^ | Functional electrical stimulation with 15 minute treatment session/day using pulse-width of 2msec scheduled for 2 seconds with 4 seconds rest, frequency of 50Hz, and power 10–100mA | Sham stimulation with inactive device. | Objectively cured from stress urinary incontinence | 3 | 3 | 15.0 | 12.5 | 1.2 (0.3; 5.3)
N = 57 | | | Subjectively cured from stress urinary incontinence | 2 | 4 | 10.0 | 16.7 | 0.6 (0.1; 2.9)
Fujishiro, 2000 ^570^ | Neuromodlation therapy: Magnetic stimulation of sacral roots with 15Hz frequency, 50% intensity output for 5 seconds per minute for 30 minutes. | Sham stimulation with inactive device | Self reported cure from stress urinary incontinence | 4 | 1 | 13.0 | 3.0 | 4.0 (0.5; 33.8)
N = 62

Bold - significant differences in outcomes at 95% confidence level;

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F102 Effects of electrical stimulation and neuromodulationon improvement of urinary incontinence in females (events) (table sorted by rate of improvement after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Outcomes | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Amaro, 2006 ^551^ | Effective Intravaginal electrical stimulation with 3 20-minute sessions/week using Dualpex Uro 996 (frequency = 4Hz) | Sham Intravaginal electrical stimulation | Self reported reduction in urge urinary incontinence | 17 | 14 | 85.0 | 68.5 | 1.2 (0.9; 1.7)
N = 40
Fujishiro, 2000 ^570^ | Neuromodulation therapy: Magnetic stimulation of sacral roots with 15Hz. frequency, 50% intensity output for 5 seconds each minute for 30 minutes | Sham stimulation with inactive device | Self reported improvement in stress urinary incontinence | 23 | 10 | 74.0 | 32.0 | 2.3 (1.3; 4.0) | 2 (1; 10) | 420 (104; 957)E
N = 62
Pages, 2001 ^553^ | Specific physical therapy program. | Biofeedback training and stimulation daily 90 minutes in group and individually for 15 minutes, 5 times/week. Intra vaginal pressure sensor and visual biofeedback in computer monitor | Fewer stress urinary incontinence episodes (-50%) and symptoms | 20 | 9 | 74.0 | 68.0 | 1.1 (0.7; 1.6)
N = 51 | Group therapy 5 times/week and home pelvic floor exercise with 50 contractions for 10 minutes 2 times/day.
| Recommendation of weight loss and aerobic sport
Spruijt, 2003 ^547^ | Intravaginal electrical stimulation of the pelvic floor using stimulator generated biphasic current pulses with a duration of ms and a frequency of 50Hz (stress urinary incontinence) or 20Hz ( urge urinary incontinence). | Kegel exercise program with verbal instructions on how to exercise at home | % of improved pelvic muscle strength | 18 | 5 | 70.8 | 44.4 | 1.7 (0.8; 3.5)
N = 51
Bower, 1998 ^569^ | Neuromodulation therapy: Active transcutaneous electrical nerve stimulation with 150Hz. frequency and 200 microsecond pulse with (suprapubic placement) | Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement | Detrusor pressure at max cystometric capacity <15cm | 11 | 6 | 68.7 | 40.0 | 1.8 (0.9; 3.7)
N = 48
Smith, 1996 ^556^ | Electrical stimulation using frequency 12.5Hz –50Hz and amplitude 5–25mA for 15 to 60 minutes 2/day | Kegel exercise | Improved urinary incontinence | 10 | 3 | 50.0 | 33.0 | 1.5 (0.5; 4.2)
N = 57
Sand, 1995 ^554^ | Active pelvic floor stimulator with gradually adjusted 60–80mA from 5 seconds on/1 sec off for 15 minutes to 5 seconds on/5 seconds off for 30 minutes. | Sham inactive device. | Improved by 50% pad test | 16 | 3 | 46.0 | 18.0 | 2.6 (0.9; 7.7)
N = 52
Indrekvam, 2001 ^555^ | Home-managed electrical stimulation with vaginal/anal stimulators (20–50Hz) for 6 –8 hours/day for at least 3 months before evaluation of the effect. | Baseline data | Reduction in frequency of urine loss: every day and/or night | 1,384 | 1865 | 46.0 | 62.0 | 0.7 (0.7; 0.8) | 6 (6; 7) | 160 (137; 181)A
N = 3,008
Spruijt, 2003 ^547^ | Intravaginal electrical stimulation of the pelvic floor using stimulator generated biphasic current pulses with duration of 1ms and a frequency of 50Hz (stress urinary incontinence) or 20Hz (urge urinary incontinence). | Kegel exercise program with verbal instructions on how to exercise at home | % with improved subjective outcome variables PRAFAB score | 11 | 5 | 45.8 | 45.4 | 1.1 (0.5; 2.4)
N = 51 | | | % with improved frequency of urine leakage | 11 | 3 | 45.8 | 27.3 | 1.8 (0.6; 5.2)
Smith, 1996 ^556^ | Electrical stimulation using frequency 12.5Hz–50Hz and amplitude 5–10mA–80mA for 15 to 60 minutes 2/day | Kegel exercise | Improved urinary incontinence | 4 | 3 | 44.0 | 33.0 | 1.3 (0.4; 4.3)
N -= 57
But, 2005 ^559^ | Functional magnetic stimulation applied continuously at 18.5Hz day and night | Sham inactive device | Improvement in mixed urinary incontinence | 11 | 3 | 41.9 | 22.9 | 1.8 (0.6; 5.4)
N = 39
Smith, 1996 ^556^ | Anticholinergic therapy with Propantheline bromide in dose of 7.5 to 45mg 2–3 times/day | Electrical stimulation using frequency 12.5Hz–50Hz and amplitude 5–25mA for 15–60 minutes 2/day | Improved urinary incontinence | 7 | 9 | 38.9 | 33.0 | 0.4 (0.2; 0.7) | -17 (4; 12) | 193 (86; 253)A
N -= 57
Sand, 1995 ^554^ | Active pelvic floor stimulator with gradually adjusted 60–80mA from 5 seconds on/1 second off for 15 minutes to 5 seconds on/5 seconds off for 30 minutes. | Sham inactive device. | Improved by 50% voiding diary | 13 | 2 | 37.0 | 12.0 | 3.2 (0.8; 12.4)
N = 52
But, 2003 ^546^ | Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz. | Placebo treatment with sham not active device. | Less abdominal pain related to urge urinary incontinence | 11 | 1 | 36.7 | 5.0 | 8.1 (1.1; 57.9) | 3 (0; 163) | 317 (6; 2,847)E
N = 52 | | | Improvement in urge urinary incontinence at night | 11 | 4 | 36.7 | 20.0 | 2.0 (0.7; 5.5)
Brubaker, 1997 ^557^ | Transvaginal electric stimulation for 20 minutes 2 times/day using frequency of 20Hz, a 2 second-4 second work-rest cycle with a range of stimulation intensities, from 0 to 100mA | Sham inactive device. | Adequate subjective improvement | 21 | 10 | 35.0 | 17.0 | 2.1 (1.1; 4.1) | 6 (2; 59) | 180 (17; 535)E
N = 148
Borawski, 2007 ^573^ | Neuromulation therapy: Electrical stimulation with percutaneous needle electrode (22-G spinal needle) placement | Electrical stimulation with surgical first stage lead placement | >50% Improvement in 24 hour pad weight for urinary incontinence | 4 | 13 | 30.8 | 76.5 | 0.4 (0.2; 0.9) | 2 (2; 25) | 457 (40; 634)A
N = 30
Spruijt, 2003 ^547^ | Intravaginal electrical stimulation of the pelvic floor using stimulator generated biphasic current pulses with duration of 1msec and a frequency of 50Hz (stress urinary incontinence) or 20Hz (urge urinary incontinence). | Kegel exercise program with verbal instructions on how to exercise at home | % with reduced amount of loss urine | 7 | 3 | 29.2 | 27.3 | 1.1 (0.3; 3.6)
N = 51 | | | % of improved/cured from urinary incontinence | 7 | 4 | 29.2 | 36.4 | 0.8 (0.3; 2.3)
But, 2003 ^546^ | Functional magnetic stimulation with Pulsegen device, which produced a pulsating magnetic field of B = 10 microT intensity and a frequency of 10Hz. | Placebo treatment with sham not active device. | Improvement in urge urinary incontinence during a day | 7 | 1 | 23.0 | 5.0 | 5.1 (0.7; 38.8)
N = 52
Spruijt, 2003 ^547^ | Intravaginal electrical stimulation of the pelvic floor using stimulator generated biphasic current pulses with duration of 1ms and a frequency of 50Hz (stress urinary incontinence) or 20Hz (urge urinary incontinence) | Kegel exercise program with verbal instructions on how to exercise at home | % improved Detrusor instability | 6 | 3 | 22.2 | 28.6 | 1.0 (0.3; 3.2)
N = 51
Borawski, 2007 ^573^ | Neuromodualtion therapy: Electrical stimulation with percutaneous needle electrode (22-G spinal needle) placement | Electrical stimulation with surgical first stage lead placement | >50% Improvement in 24 hour pad usage for urinary incontinence | 2 | 11 | 15.4 | 64.7 | 0.2 (0.1; 0.9) | 2 (2; 14) | 493 (70; 606)A
N = 30
Luber, 1997 ^561^ | Functional electrical stimulation with 15 minute treatment session/day using pulse-width of 2msec scheduled for 2 seconds with 4 seconds rest, frequency of 50Hz, and power 10–100mA | Sham stimulation with inactive device. | Subjectively improvement in stress urinary incontinence | 3 | 3 | 15.0 | 12.5 | 1.2 (0.3; 5.3)
N = 57
Borawski, 2007 ^573^ | Neuromodulation therapy: Electrical stimulation with percutaneous needle electrode (22-G spinal needle) placement | Electrical stimulation with surgical first stage lead placement | >50% Improvement in daily incontinence episodes | 1 | 14 | 7.7 | 82.4 | 0.1 (0.0; 0.6) | 1 (1; 3) | 747 (311; 812)A
N = 30

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F103 Effects of stimulation therapy on urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Indrekvam, 2001 ^555^ | Home-managed electrical stimulation with vaginal/anal stimulators (20–50Hz) for 6–8 hours/day for at least 3 months before evaluation of the effect | Baseline data | Frequency of urine loss: every day and/or night | 1,384 | 1,865 | 46.0 | 62.0 | 0.7 (0.7; 0.8) | 6 (6; 7) | 160 (137;181)A
N = 3,008 | | | Pad use during 24 hours >5 | 331 | 361 | 11.0 | 12.0 | 0.9 (0.8; 1.1)
| | | Patients' assessment of impact: much bothered | 391 | 632 | 13.0 | 21.0 | 0.6 (0.6; 0.7) | 13 (11; 16) | 80 (64; 94)A
| | | Severity index: moderate | 361 | 90 | 12.0 | 3.0 | 4.0 (3.2; 5.0)
| | | Severity index: severe | 1053 | 1,444 | 35.0 | 48.0 | 0.7 (0.7; 0.8) | 8 (7; 9) | 130 (108; 151)A
| | | Two or more voidings during the night | 1023 | 1,173 | 34.0 | 39.0 | 0.9 (0.8; 0.9) | 20 (14; 38) | 50 (26; 72)A
| | | Usual amount of leakage: substantial amounts | 331 | 451 | 11.0 | 15.0 | 0.7 (0.6; 0.8) | 25 (19; 41) | 40 (24; 54)A
Stamp, 2001 ^574^ | Massage and stretching of perineum during second stage of labor with a water soluble lubricant | Usual care | Urinary incontinence 3 months postpartum | 123 | 115 | 17.4 | 18.2 | 1.0 (0.8; 1.2)
N = 1,340
Spruijt, 2003 ^547^ | Intravaginal electrical stimulation of the pelvic floor using stimulator generated biphasic current pulses with duration of 1msec and frequency of 50Hz (stress urinary incontinence) or 20Hz (urge urinary incontinence) | Kegel exercise program with verbal instructions on how to exercise at home | % with deterioration of urinary incontinence | 6 | 7 | 25.0 | 54.5 | 0.4 (0.2; 1.0) | 3 (2; 44) | 295 (23; 449)A
N = 51 | | | % with unchanged urinary incontinence | 11 | 1 | 45.8 | 9.1 | 5.3 (0.8; 36.3)
Amaro, 2005 ^558^ | Intravaginal electrical stimulation with 3 20-minute sessions/week using 4Hz frequency. | Sham stimulation with inactive device. | Urge urinary incontinence at 1 month followup | 3 | 6 | 15.0 | 31.5 | 0.5 (0.1; 1.7)
N = 40
But, 2005 ^559^ | Functional magnetic stimulation applied continuously at 18.5Hz day and night | Sham inactive device | Incidence of idiopathic detrusor over activity | 1 | 3 | 3.8 | 23.1 | 0.2 (0.0; 1.4)
N = 39
Emmons, 2005 ^562^ | Acupuncture treatment expected to improve bladder symptoms | Placebo acupuncture treatment designed to promote relaxation | Proportion of subjects with detrusor contractions during cystometry | 7 | 11 | 16.0 | 28.0 | 0.6 (0.3; 1.4)
N = 85
Amaro, 2006 ^551^ | Effective Intravaginal electrical stimulation using frequency of 4Hz with 3 20-minute sessions/week | Sham Intravaginal electrical stimulation using frequency of 4Hz with 3 20-minute sessions/week | Self reported urge incontinence | 3 | 6 | 15.0 | 31.5 | 0.5 (0.1; 1.7)
N = 40
Brubaker, 1997 ^557^ | Transvaginal electric stimulation for 20 minutes 2 times/day using frequency of 20Hz, a 2 second–4 second work-rest cycle with range of stimulation intensities, from 0–100mA | Sham inactive device. | Final urodynamic diagnosis of detrusor over activity | 16 | 25 | 27.0 | 41.0 | 0.6 (0.4; 1.1)
N = 148
Bower, 1998 ^569^ | Neuromodulation therapy: Active transcutaneous electrical nerve stimulation with 150Hz. frequency and 200 microsecond pulse with suprapubic placement | Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement | Detrusor pressure at maximum cystometric capacity <15cm | 11 | 6 | 68.7 | 40.0 | 1.8 (0.9; 3.7)
N = 48 | | | Maximum detrusor pressure <15cm | 7 | 2 | 43.7 | 13.3 | 3.5 (0.9; 14.3)
| | | Change in detrusor pressure at first desire to void | 7 | 2 | 44.0 | 13.0 | 3.5 (0.9; 14.3)
| | | Change in detrusor pressure at first desire to void | 7 | 2 | 44.0 | 13.0 | 3.5 (0.9; 14.3)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F104 Effects of electrical stimulation or neuromodulation therapy on urinary continence in adults (events) (sorted by rate of continence after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Definition of Continence | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Schmidt, 1999 ^566^ | Neuromodulation therapy: Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place. | Standard medical therapy | Self reported urge urinary continence (cured) | 24 | 0 | 47.0 | 1.0 | 43.5 (2.7; 695.0) | 2 (0; 58) | 460 (17; 6,940)E
N = 98
81% female
Weil, 2000 ^567^ | Neuromodulation therapy: Sacral root neuromodulation with an implantable impulse generator | Prior conservative management: medications or pelvic floor exercise | Self reported urge urinary continence (cured) | 9 | 1 | 42.9 | 4.3 | 9.9 (1.4; 71.4) | 3 (0; 64) | 385 (16; 3,059)E
N = 44
91% female
Yamanishi, 2000 ^548^ | Electrical stimulation 15 minutes twice daily for 4 weeks (vaginal electrode in women and an anal or surface electrode in men to provide alternating pulses of 10Hz square waves of 1ms pulse duration and a maximum output current of 60mA). | Sham inactive device | Urinary continence (cured) | 7 | 1 | 18.9 | 3.2 | 5.9 (0.8 (45.1)
N = 68
57% female
Karademir, 2005 ^568^ | Neuromodulation therapy: Stoller afferent neurostimulation with frequency 20Hz and amplitude 0.5–10mA | Stoller afferent neuronstimulation with frequency 20Hz and amplitude 0.5–10mA combined with 5mg of oral oxybutynin hydrochloride | Cured from urge incontinence | 3 | 3 | 14.3 | 13.0 | 1.1 (0.2; 4.8)
N = 43
88% female
Yamanishi, 1997 ^563^ | Electrical pelvic stimulation with 50Hz square waves of 1msec. pulse duration and vaginal electrode in women and an anal electrode in men for 15 minutes 2 or 3 times daily | Sham electrical pelvic stimulation with inactive device | Cured | 2 | 0 | 8.0 | 1.0 | 3.3 (0.2; 64.3)
N = 35
86% female

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F105 Effects of electrical stimulation and neuromodulation therapy on improvement of urinary incontinence (events) (table sorted by rate of improvement after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Schmidt, 1999 ^566^ | Neuromodulation therapy: Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place | Standard medical therapy | Improvement in severity: heavy urge incontinence at baseline and none at 6 months | 40 | 4 | 77.0 | 8.0 | 8.8 (3.4; 22.8) | 1 (1; 5) | 690 (194; 1,747)E
N = 98
81% female
Karademir, 2005 ^568^ | Neuromodulation therapy: Stoller afferent neurostimulation with frequency 20Hz and amplitude 0.5–10mA | Stoller afferent neurostimulati on with frequency 20Hz and amplitude 0.5–10mA combined with 5mg of oral oxybutynin hydrochloride | % decrease in symptoms of urge incontinence | 15 | 20 | 70.2 | 89.7 | 0.8 (0.6; 1.1)
N = 43
88% female
Schmidt, 1999 ^566^ | Neuromodulation therapy: Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place. | Standard medical therapy | Self reported no use of absorbent pads or diapers for urge urinary incontinence | 26 | 1 | 50.0 | 2.0 | 23.0 (3.2; 162.9) | 2 (0; 22) | 480 (45; 3,238)E
N = 98
81% female
Karademir, 2005 ^568^ | Neuromodulation therapy: Stoller afferent neurostimulation with frequency 20Hz and amplitude 0.5–10mA | Stoller afferent neurostimulation with frequency 20Hz and amplitude 0.5–10mA combined with 5mg of oral oxybutynin hydrochloride | % decrease in symptoms of urgency | 10 | 13 | 46.1 | 61.1 | 0.8 (0.5; 1.4)
N = 43 | | | % decrease in symptoms of frequency | 8 | 10 | 36.7 | 44.2 | 0.8 (0.4; 1.7)
88% female
Schmidt, 1999 ^566^ | Neuromodulation therapy: Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place | Standard medical therapy | Significant reduction in daily urge urinary incontinence episodes (>50%) | 15 | 2 | 29.0 | 5.0 | 6.6 (1.6; 27.5) | 4 (1; 33) | 240 (30; 1,324)E
N = 98
81% female
Yamanishi, 2000 ^548^ | Electrical stimulation 15 minutes twice daily for 4 weeks (vaginal electrode in women and an anal or surface electrode in men to provide alternating pulses of 10Hz square waves of 1ms pulse duration and a maximum output current of 60mA) | Sham inactive device | No Detrusor overactivity | 8 | 2 | 21.6 | 6.5 | 3.4 (0.8; 14.6)
N = 68
57% female
Yamanishi, 2000 ^549^ | Functional magnetic stimulation applied continuously at 10Hz | Functional electrical stimulation applied continuously at 10Hz with vaginal electrode in women and a surface electrode on the dorsal part of the penis in men. | Abolished detrusor overactivity | 3 | 0 | 20.0 | 0.5 | 7.9 (0.4; 141.1)
N = 32
54% female
Yamanishi, 1997 ^563^ | Electrical pelvic stimulation with 50Hz. square waves of 1ms. pulse duration and vaginal electrode in women and an anal electrode in men for 15 minus 2 or 3 times/day | Sham electrical pelvic stimulation with inactive device | Improved: decrease >50% in pad test | 3 | 0 | 13.0 | 3.0 | 4.7 (0.3; 83.5)
N = 35 | | | Improved: decrease in urinary leakage >50% | 2 | 0 | 11.0 | 2.0 | 3.3 (0.2; 64.3)
86% female

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F106 Effects of electrical stimulation or neuromodulation on perceived urinary incontinence in females (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Differences (95% CI) | % Change from Baseline (95% CI)
Sample
Brubaker, 1997 ^557^ | Transvaginal electric stimulation for 20 minutes 2 times/day using frequency of 20Hz, a 2-second, 4-second work-rest cycle with a range of stimulation intensities, from 0 to 100mA | Sham inactive device | Number of urinary accidents/24 hour (average) | 2.4 ± 3.1 | 2.2 ± 2.7 | 0.1 (-0.3; 0.4) | 3.1 (-13.1; 19.3)
N = 148
Smith, 1996 ^556^ | Electrical stimulation using frequency 12.5H – 50Hz and amplitude 5–10mA–80mA for 15 to 60 minutes 2/day | Kegel exercise | Leaks/24hours | 2.4 ± 2.4 | 1.4 ± 2.4 | 0.4 (-0.5; 1.4) | 29.8 (-37.0; 96.6)
N = 57 | Anticholinergic therapy with Propantheline bromide in dose of 7.5 to 45mg 2–3 times/day | Electrical stimulation using frequency 12.5Hz–50Hz and amplitude 5–25mA for 15 to 60 minutes 2/day | Pads use/week | 8.1 ± 5.3 | 6.5 ± 7.7 | 0.2 (-0.4; 0.9) | 3.8 (-6.1; 13.6)
| Electrical stimulation using frequency 12.5Hz.–50 Hz and amplitude 5–10mA–80mA for 15 to 60 minutes 2/day | Kegel exercise | Pads use/week | 5.4 ± 3.1 | 4.0 ± 4.0 | 0.4 (-0.5; 1.3) | 9.8 (-13.6; 33.1)
Sand, 1995 ^554^ | Active pelvic floor stimulator with gradually adjusted 60–80mA from 5 seconds on, 1 second off for 15 minutes to 5 seconds on, 5 seconds off for 30 minutes | Sham inactive device | Urinary leaks/24 hours | 1.8 ± 2.5 | 3.8 ± 3.1 | -0.7 (-1.3; -0.1) | -19.2 (-34.9; -3.5)
N = 52 | | | Urinary leaks/week | 10.0 ± 14.5 | 27.0 ± 53.8 | -0.5 (-1.1; 0.1) | -1.9 (-4.1; 0.3)
Pages, 2001 ^553^ | Specific physical therapy program. Group therapy 5 times/week and home pelvic floor exercise with 50 contractions for 10 minutes 2 times/day. Recommendation of weight loss and aerobic sports. | Biofeedback training daily 90 minutes in group and individually for 15 minutes, 5 times/week. Intra vaginal pressure sensor and visual biofeedback in computer monitor. | Nocturnal urination frequency | 0.3 ± 0.5 | 0.4 ± 0.4 | -0.1 (-0.7; 0.6) | -22.4 (-196.6; 151.8)
N = 51 | | | digital contraction strength: cough scores (1–5) | 4.0 ± 0.9 | 4.0 ± 0.6 | 0.0 (-0.7; 0.7) | 0.0 (-16.5; 16.5)
| | | Digital contraction strength: voluntary contraction scores (1–5) | 3.5 ± 1.0 | 4.0 ± 0.8 | -0.5 (-1.2; 0.1) | -13.3 (-30.1; 3.5)
Sand, 1995 ^554^ | Active pelvic floor stimulator with gradually adjusted 60–80mA from 5 seconds on, 1 second off for 15 minutes to 5 seconds on, 5 seconds off for 30 minutes | Sham inactive device | Pad use/week | 4.1 ± 5.3 | 11.2 ± 16.8 | -0.7 (-1.3; -0.1) | -6.1 (-11.4; -0.8)
N = 52
Dumoulin, 2004 ^489^ | Electrical stimulation of the pelvic floor + pelvic floor muscle exercise + biofeedback | Relaxation massage for the back and extremities | Change from baseline in VAS (from 10 possible) | 2.5 2.0 | 0.0 ± 0.0 | 1.7 (1.0; 2.5)
N = 64 | | | Change from baseline in Urogenital Distress Inventory (from 57 possible) | 7.0 ± 0.8 | 0.0 ± 5.2 | 1.9 (1.2; 2.6)
| | | Change from baseline in Incontinence Impact Questionnaire (from 90 possible) | 13.0 ± 9.6 | 0.5 ± 3.6 | 1.7 (1.0; 2.4) | 341.6 (197.5; 485.6)
| | | Change from baseline in Urogenital Distress Inventory (from 57 possible) | 4.0 ± 4.8 | 0.0 ± 5.2 | 0.8 (0.2; 1.4)
| | | Change from baseline in Incontinence Impact Questionnaire (from 90 possible ) | 10.0 ± 4.8 | 0.5 ± 3.6 | 2.2 (1.4; 3.0) | 446.2 (288.7; 603.7)
Jarvis, 2005 ^575^ | Preoperative physiotherapy | No preoperative physiotherapy | Self reported scores of symptoms of urinary incontinence | | | -3.8 (-0.7; -6.9)
N = 60
Barroso, 2004 ^564^ | Transvaginal electrical stimulation at home twice a day (20-minute sessions) with frequency of 20 (urge) or 50Hz (stress), a pulse width of 300ms, with asymmetrical biphasic pulses, an adjustable current intensity (0–100mA). | Placebo (identical equipment but with no electrical current) | Number of episodes of voiding urgency. | 1.5 ± 1.8 | 6.5 ± 2.4 | -2.5 (-3.4; -1.6) | -38.2 (-52.2; -24.2)
N = 34 | | | Urinary leakage | 1.3 ± 1.0 | 3.0 ± 0.9 | -1.8 (-2.6; -0.9) | -58.5 (-85.5; -31.5)
| | | Number of nocturnal voids | 1.1 ± 0.5 | 2.3 ± 0.9 | -1.8 (-2.6; -1.0) | -79.5 (-115.0; -43.9)
Emmons, 2005 ^562^ | Acupuncture treatment expected to improve bladder symptoms | Placebo acupuncture treatment designed to promote relaxation | Incontinence impact questionnaire score | 4.3 ± 2.7 | 7.0 ± 3.5 | -0.9 (-1.3; -0.4) | -12.4 (-18.8; -6.0)
N = 85 | | | Urinary distress inventory score | 3.6 ± 3.2 | 5.8 ± 4.8 | -0.5 (-1.0; -0.1) | -9.4 (-16.8; -1.9)
| | | Number of total urinary incontinent episodes/3 days) | 2.6 ± 3.1 | 5.3 ± 5.9 | -0.6 (-1.0; -0.1) | -10.9 (-19.1; -2.7)
Fujishiro, 2000 ^570^ | Neuromodulation therapy: Magnetic stimulation of sacral roots with 15Hz frequency, 50% intensity output for 5 seconds per minute for 30 minutes. | Sham stimulation with inactive device | Number of stress urinary leakage episodes/3 days | 2.2 ± 3.6 | 3.2 ± 2.9 | -0.3 (-0.8; 0.2) | -9.6 (-25.2; 6.1)
N = 62
Dumoulin, 2004 ^489^ | Electrical stimulation of the pelvic floor + pelvic floor muscle exercise + biofeedback | Relaxation massage for the back and extremities | Change from baseline in VAS (from 10 possible ) | 3.0 ± 0.8 | 0.0 ± 0.0 | 5.2 (3.9; 6.5)
N = 64
Emmons, 2005 ^562^ | Acupuncture treatment expected to improve bladder symptoms | Placebo acupuncture treatment designed to promote relaxation | Number of urge urinary episodes/3 days) | 11.4 ± 8.8 | 15.0 ± 9.4 | -0.4 (-0.8; 0.0) | -2.6 (-5.5; 0.2)
N = 85
Luber, 1997 ^561^ | Functional electrical stimulation with 15-minute treatment sessions per day using pulse-width of 2msec scheduled for 2 seconds with 4 second rest, frequency of 50Hz, and power 10–100mA | Sham stimulation with inactive device | Stress urinary incontinence episodes/ 24hours | 2.4 ± 4.4 | 2.4 ±5.7 | 0.0 (-0.6; 0.6) | 0.0 (-24.7; 24.7)
N = -57
Fujishiro, 2002 ^571^ | Neuromodulation therapy: Magnetic stimulation of sacral roots with 15Hz. frequency, 50% intensity output for 5 seconds per minute for 30 minutes | Sham stimulation with inactive device | Number of urinary voids/daily | 9.3 ± 2.3 | 10.0 ± 2.0 | -0.3 (-1.0; 0.3) | -3.2 (-9.8; 3.4)
N = 37 | | | Number of urge urinary leakage episodes/3 days | 1.6 ± 3.2 | 1.6 ± 1.2 | 0.0 (-0.7; 0.7) | 0.0 (-41.0; 41.0)

Bold- significant differences in outcomes at 95% confidence level

Table F107 Effects of electrical stimulation or neuromodulation therapy on urinary incontinence in females (pad test and urodynamic evaluations)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Smith, 1996 ^556^ | Anticholinergic therapy with Propantheline bromide in dose of 7.5 to 45mg 2 – 3 times/day | Electrical stimulation using frequency 12.5Hz.–50Hz and amplitude 5–25mA for 15 to 60 minutes 2/day | Bladder capacity, ml | 220.0 ± 253.3 | 247.0 ± 235.3 | -0.1 (-0.7; 0.5) | 0.0 (-0.3; 0.2)
N = 57
Bower, 1998 ^569^ | Neuromodulation therapy: Active transcutaneous electrical nerve stimulation with 10Hz. frequency and 200 microsecond pulse width (sacral placement) | Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement | First desire to void | 154.0 ± 61.0 | 186.0 ± 77.0 | -0.5 (-1.2; 0.2) | -0.2 (-0.6; 0.1)
N = 48
Amaro, 2005 ^558^ | Intravaginal electrical stimulation with 3 20-minute sessions/week using 4Hz frequency | Sham stimulation with inactive device | Vaginal cone weight test | 4.0 ± 1.3 | 2.0 ± 1.1 | 1.7 (0.9; 2.4) | 83.0 (46.9; 119.2)
N = 40
Smith, 1996 ^556^ | Electrical stimulation using frequency 12.5Hz.–50Hz and amplitude 5–10mA–80mA for 15 to 60 minutes 2/day | Kegel exercise | Leak point pressure | 95.0 ± 23.3 | 105.0 ± 16.7 | -0.5 (-1.4; 0.4) | -0.5 (-1.4; 0.4)
N = 57
Bower,. 1998 ^569^ | Neuromodulation therapy: Active transcutaneous electrical nerve stimulation with 150Hz. frequency and 200 microsecond pulse with (suprapubic placement) | Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement | Max Detrusor pressure | 18.2 ± 10.2 | 26.0 ± 12.3 | -0.7 (-1.4; 0.0) | -2.7 (-5.4; 0.1)
N = 48
Amaro, 2005 ^558^ | Intravaginal electrical stimulation with 3 20-minute sessions/week using 4Hz frequency | Sham stimulation with inactive device | Perineal muscle strength | 53.8 ± 18.6 | 46.8 ± 12.5 | 0.4 (-0.2; 1.1) | 0.9 (-0.4; 2.3)
N = 40
Bower, 1998 ^569^ | Neuromodulation therapy: Active transcutaneous electrical nerve stimulation with 10Hz. frequency and 200 microsecond pulse width (sacral placement) | Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement | Change from baseline in max Detrusor pressure | 12.7 ± 16.9 | 1.4 ± 4.9 | 0.9 (0.2; 1.6) | 64.9 (12.7; 117.0)
N = 48 | | | Change from baseline in max Detrusor pressure | 7.0 ± 11.0 | 1.4 ± 4.9 | 0.7 (-0.1; 1.4) | 47.0 (-3.9; 97.9)
| | | Threshold volume | 224.0 ± 141.0 | 262.0 ±105.0 | -0.3 (-1.0; 0.4) | -0.1 (-0.4; 0.1)
| | | Maximum Detrusor pressure | 21.7 ± 17.2 | 26.0 ± 12.3 | -0.3 (-1.0; 0.4) | -1.1 (-3.8; 1.6)
| | | Detrusor pressure at maximum cystometric capacity | 15.1 ± 10.1 | 21.5 ± 12.2 | -0.6 (-1.3; 0.1) | -2.7 (-5.9; 0.6)
| | | Detrusor pressure at maximum cystometric capacity | 12.8 ± 8.1 | 21.5 ± 12.2 | -0.8 (-1.6; -0.1) | -3.9 (-7.3; -0.6)
| | | Detrusor pressure at first desire to void | 11.3 ± 15.7 | 10.7 ± 9.5 | 0.0 (-0.7; 0.7) | 0.4 (-6.1; 6.9)
| | | Detrusor pressure at first desire to void | 7.3 ± 6.6 | 10.7 ± 9.5 | -0.4 (-1.1; 0.3) | -3.9 (-10.5; 2.6)
| | | Maximum cystometric capacity | 305.0 ± 146.0 | 313.5 ± 81.0 | -0.1 (-0.8; 0.6) | 0.0 (-0.2; 0.2)
| | | Threshold volume | 295.0 ± 162.0 | 262.0 ± 105.0 | 0.2 (-0.5; 0.9) | 0.1 (-0.2; 0.4)
Berghmans, 2002 ^552^ | Office- and home-based functional electro-stimulation maximum 100mA frequency 4–10Hz | No treatment | Detrusor Activity Index | 0.6 ± 0.3 | 0.8 ± 0.3 | -0.8 (-1.5; 0.0) | -95.6 (-187.4; -3.8)
N = 98 | Pelvic floor exercises with contractions for >20 seconds, relaxation for 10 seconds. Bladder training, voiding schedule, and positive reinforcement | No treatment | Detrusor Activity Index | 0.6 ± 0.3 | 0.8 ± 0.3 | -0.6 (-1.3; 0.1) | -74.6 (-163.9; 14.7)
Sand, 1995 ^554^ | Active pelvic floor stimulator with gradually adjusted 60–80mA from 5 seconds on, 1-second off for 15 minutes to 5 seconds on, 5 seconds off for 30 minutes. | Sham inactive device. | Vaginal muscle strength (mm/Hg) | 15.2 ± 15.1 | 8.9 ± 7.2 | 0.5 (-0.1; 1.1) | 5.4 (-1.2; 12.0)
N = 52 | | | Pad weight (g) | 15.4 ± 26.0 | 32.3 ± 43.0 | -0.5 (-1.1; 0.1) | -1.6 (-3.4; 0.2)
| | | Maximum cystometric capacity (ml) | 494.6 ± 236.9 | 496.6 ± 225.3 | 0.0 (-0.6; 0.6) | 0.0 (-0.1; 0.1)
| | | Residual urine (ml) | 23.8 ± 34.1 | 12.9 ± 18.8 | 0.4 (-0.2; 0.9) | 2.8 (-1.7; 7.3)
Berghmans, 2002 ^552^ | Office-based functional electro stimulation, pelvic floor exercise, and bladder training | No treatment | Detrusor Activity Index | 0.8 ± 0.3 | 0.8 ± 0.3 | 0.2 (-0.6; 0.9) | 18.8 (-69.7; 107.4)
N = 98
Pages, 2001 ^553^ | Specific physical therapy program. Group therapy 5 times/week and home pelvic floor exercise with 50 contractions for 10 minutes 2 times/day. Recommendation of weight loss and aerobic sports | Biofeedback training daily for 90 minutes in group and individually for 15 minutes, 5 times/week. | Maximum forced cough pressure cm/H2O | 38.0 ± 22.0 | 55.0 ± 12.0 | -0.9 (-1.6; -0.2) | -1.6 (-2.8; -0.3)
N = 51 | | Intra vaginal pressure sensor and visual biofeedback in computer monitor. | Maximum contraction pressure cm/H2O | 38.0 ± 22.0 | 75.0 ± 21.0 | -1.7 (-2.5; -0.9) | -2.3 (-3.3; -1.3)
| | | Average contraction pressure cm/H2O | 16.0 ± 10.0 | 50.0 ± 14.0 | -3.0 (-3.9; -2.0) | -6.0 (-7.8; -4.1)
Bower, 1998 ^569^ | Neuromodulation therapy: Active transcutaneous electrical nerve stimulation with 150Hz frequency and 200 microsecond pulse with (suprapubic placement) | Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement | Maximum cystometric capacity | 352.0 ± 145.0 | 313.5 ± 81.0 | 0.3 (-0.4; 1.0) | 0.1 (-0.1; 0.3)
N = 48
Dumoulin, 2004 ^489^ | Electrical stimulation of the pelvic floor + pelvic floor muscle exercise + biofeedback | Relaxation massage for the back and extremities | Change from baseline in pelvic floor muscle maximum strength (N) | 0.5 ± 1.6 | -0.5 ± 1.2 | 0.7 (0.0; 1.3) | -140.7 (-9.4; -272.1)
N = 64 | | | Change from baseline pad test (g) | 19.0 ± 4.8 | 0.0 ± 7.8 | 3.0 (2.1; 3.8)
Bower, 1998 ^569^ | Neuromodulation therapy: Active transcutaneous electrical nerve stimulation with 150Hz. frequency and 200 microsecond pulse with (suprapubic placement) | Sham transcutaneous electrical nerve stimulation with sacral or suprapubic placement | First desire to void | 208.0 ± 132.0 | 186.0 ± 77.0 | 0.2 (-0.5; 0.9) | 0.1 (-0.3; 0.5)
N = 48
Dumoulin, 2004 ^489^ | Electrical stimulation of the pelvic floor + pelvic floor muscle exercise + biofeedback | Relaxation massage for the back and extremities | Change from baseline in pelvic floor muscle maximum strength (N) | 0.7 ± 1.3 | -0.5 ± 1.2 | 0.9 (0.3; 1.6) | -194.1 (-59.5; -328.8)
N = 64 | | | Change from baseline in maximum rate of force development (N/s) | 0.8 ± 1.7 | -0.5 ± 1.0 | 0.9 (0.3; 1.6) | -201.3 (-60.8; -341.7)
Jarvis, 2005 ^575^ | Preoperative physiotherapy | No preoperative physiotherapy | Leakage at paper towel test (cm2) | | | 30 (-11; 72.3)
N = 60
Dumoulin, 2004 ^489^ | Electrical stimulation of the pelvic floor + pelvic floor muscle exercise + biofeedback | Relaxation massage for the back and extremities | Change from baseline in pad test (g) | 8.0 ± 13.8 | 0.0 ± 7.8 | 0.7 (0.1; 1.3)
N = 64
Barroso, 2004 ^564^ | Transvaginal electrical stimulation at home twice a day (20-minute sessions) with frequency of 20 (urge) or 50Hz (stress), a pulse width of 300msec, with asymmetrical biphasic pulses, an adjustable current intensity (0–100mA) | Placebo (identical equipment but with no electrical current) | First desire to void, ml | 161.3 ± 43.3 | 150.8 ± 42.5 | 0.2 (-0.5; 0.9) | 0.2 (-0.3; 0.6)
N = 34 | | | Maximum bladder capacity, ml | 425.0 ± 97.8 | 316.7 ± 71.8 | 1.2 ( 0.5; 1.9) | 0.4 (0.1; 0.6)
Dumoulin, 2004 ^489^ | Electrical stimulation of the pelvic floor + pelvic floor muscle exercise + biofeedback | Relaxation massage for the back and extremities | Change from baseline in maximum rate of force development (N/s) | 0.3 ± 1.3 | -0.5 ± 1.0 | 0.7 (0.0; 1.3) | -145.4 (-8.4; -282.4)
N = 64
Emmons, 2005 ^562^ | Acupuncture treatment expected to improve bladder symptoms | Placebo acupuncture treatment designed to promote relaxation | Functional bladder capacity | 236.0 ± 99.0 | 196.0 ± 85.0 | 0.4 (0.0; 0.9) | 0.2 (0.0; 0.4)
N = 85
Fujishiro, 2000 ^570^ | Neuromodulation therapy: Magnetic stimulation of sacral roots with 15Hz frequency, 50% intensity output for 5 seconds per minute for 30 minutes | Sham stimulation with inactive device | Urine loss on pad test (gm) | 5.5 ± 7.5 | 8.0 ±6.8 | -0.3 (-0.9; 0.2) | -4.4 (-10.6; 1.9)
N = 62
Emmons, 2005 ^562^ | Acupuncture treatment expected to improve bladder symptoms | Placebo acupuncture treatment designed to promote relaxation | Cystometric maximum capacity (ml) | 415.0 ± 205.0 | 356.0 ± 193.0 | 0.3 (-0.1; 0.7) | 0.1 (0.0; 0.2)
N = 85
Luber, 1997 ^561^ | Functional electrical stimulation with 15-minute treatment sessions per day using pulse-width of 2msec scheduled for 2 seconds with 4 second rest, frequency of 50Hz, and power 10–100mA | Sham stimulation with inactive device | Valsalva leakpoint pressure, cmH20 | 86.0 ± 27.3 | 80.0 ± 116.7 | 0.1 (-0.5; 0.7) | 0.1 (-0.7; 0.8)
N = 57 | | | Cystometrogram maximum volume, cm3 | 470.0 ± 106.7 | 465.0 ± 116.7 | 0.0 (-0.5; 0.6) | 0.0 (-0.1; 0.1)
| | | Postvoid residual volume | 23.0 ± 8.0 | 19.0 ± 11.3 | 0.4 (-0.2; 1.0) | 2.1 (-1.0; 5.3)
Fujishiro, 2002 ^571^ | Neuromodulation therapy: Magnetic stimulation of sacral roots with 15 Hz frequency, 50% intensity output for 5 seconds per minute for 30 minutes | Sham stimulation with inactive device | Mean urine volume/void, ml | 195.2 ± 51.3 | 193.9 ± 47.5 | 0.0 (-0.6; 0.7) | 0.0 (-0.3; 0.4)
N = 37
Bo, 1997 ^560^ | Electrical stimulation with Conmax 50Hz - pulse width 0.75ms, 0–90mA | Electrical stimulation with Medicon 50Hz - pulse width 0.5ms, 0–100mA | Change in maximum urethral pressure during voluntary pelvic floor muscle contraction | 15.2 ± 11.5 | 10.4 ± 6.2 | 0.5 (-0.3; 1.3) | 5.0 (-2.8; 12.8)
N = 12
Emmons, 2005 ^562^ | Acupuncture treatment expected to improve bladder symptoms | Placebo acupuncture treatment designed to promote relaxation | Cystometric volume at first urge to void (ml) | 65.0 ± 80.0 | 57.0 ± 75.0 | 0.1 (-0.3; 0.5) | 0.2 (-0.6; 0.9)
N = 85 | | | Cystometric volume at strong urge to void (ml) | 297.0 ± 167.0 | 276.0 ± 156.0 | 0.1 (-0.3; 0.6) | 0.0 (-0.1; 0.2)

Bold- significant differences in outcomes at 95% confidence level

Table F108 Effects of electrical stimulation or neuromodulation therapy on self reported severity of urinary incontinence in adults

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Weil, 2000 ^567^ | Neuromodulation therapy: Sacral root neuromodulation with an implantable impulse generator | Prior conservative management: medications or pelvic floor exercise | Pad use for urge urinary incontinence | 0.7 ± 1.4 | 6.8 ± 4.2 | -1.9 (-2.7; -1.2) | -28.4 (-39.0; -17.8)
N = 44 | | | Urinary leakage severity | 1.6 ± 1.9 | 2.1 ± 0.7 | -0.4 (-1.0; 0.2) | -17.1 (-45.5; 11.3)
91% female | | | Leakage episodes of urge urinary incontinence | 1.4 ± 4.2 | 11.2 ± 5.6 | -2.0 (-2.7; -1.2) | -17.5 (-24.0; -11.0)
Yamanishi, 1997 ^563^ | Electrical pelvic stimulation with 50Hz. square waves of 1ms. pulse duration and vaginal electrode in women and an anal electrode in men for 15 minutes 2 or 3 times/day | Sham electrical pelvic stimulation with inactive device | Frequency of pad change: 0- no change 3- >3 times | 1.1 ± 1.3 | 2.0 ± 1.2 | -0.7 (-1.4; 0.0) | -35.7 (-71.7; 0.4)
N = 35 | | | Disturbance in daily activities: 0- not at all, 3- very disturbed | 1.0 ± 1.2 | 2.1 ± 1.0 | -1.0 (-1.7; -0.2) | -46.5 (-81.7; -11.3)
86% female
Schmidt, 1999 ^566^ | Neuromodulation therapy: Implantation of multiprogrammable neurostimulator subcutaneously in lower quadrant of the abdomen with lead positioned to target sacral nerve and anchored in place | Standard medical therapy | Severity rank of urge urinary incontinence | 0.8 ± 0.9 | 2.0 ± 0.6 | -1.6 (-2.0; -1.1) | -77.5 (-100.2; -54.9)
N = 98 | | | Absorbent pads or diapers replaced daily due to urge urinary incontinence | 1.1 ± 2.0 | 6.3 ± 3.6 | -1.8 (-2.3; -1.3) | -28.8 (-36.3; -21.3)
81% female | | | Self reported urge urinary Incontinent episodes/day | 2.6 ± 5.1 | 11.3 ± 5.9 | -1.6 (-2.0; -1.1) | -14.0 (-18.1; -10.0)
Yamanishi, 2000 ^548^ | Electrical stimulation 15 minutes twice daily for 4 weeks (vaginal electrode in women and an anal or surface electrode in men to provide alternating pulses of 10Hz square waves of 1msec pulse duration and a maximum output current of 60mA) | Sham inactive device | Self reported scores of urinary urgency (0-none, 3-very much) | 1.7 ± 0.7 | 2.0 ± 0.8 | -0.4 (-0.9; 0.1) | -20.1 (-44.2; 4.0)
N = 68 | | | Daily frequency of pad changes for urinary incontinence | 0.8 ± 1.2 | 1.1 ± 2.0 | -0.2 (-0.7; 0.3) | -16.9 (-60.4; 26.6)
57% female

Bold- significant differences in outcomes at 95% confidence level

Table F109 Effects of electrical stimulation or neuromodulation therapy on urinary incontinence in adults (urodynamic evaluations)

Author | Active | Control | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Yamanishi, 1997 ^563^ | Electrical pelvic stimulation with 50Hz. square waves of 1ms. pulse duration and vaginal electrode in women and an anal electrode in men for 15 minutes 2 or 3 times daily | Sham electrical pelvic stimulation with inactive device | Average flow rate, ml/second | 9.7 ± 6.9 | 7.4 ± 8.3 | 0.3 (-0.4; 1.0) | 4.2 (-5.3; 13.7)
N = 35 | | | Bladder compliance at maximum sensation, cm | 91.9 ± 142.8 | 92.1 ± 107.2 | 0.0 (-0.7; 0.7) | 0.0 (-0.8; 0.8)
86% female | | | Maximum flow rate, ml/sec | 22.0 ± 10.9 | 20.6 ± 18.4 | 0.1 (-0.6; 0.8) | 0.5 (-2.9; 3.9)
| | | Functional profile length, cm | 2.3 ± 0.8 | 2.1 ± 0.9 | 0.2 (-0.5; 0.9) | 11.3 (-22.0; 44.7)
| | | Maximum urethral closure pressure, cm H20 | 52.5 ±27.0 | 35.9 ± 15.8 | 0.7 (0.0; 1.4) | 2.0 (0.0; 4.0)
| | | Bladder capacity at first sensation, ml | 214.3 ± 96.0 | 240.0 ± 42.2 | -0.3 (-1.0; 0.4) | -0.1 (-0.4; 0.2)
| | | Bladder capacity at maximum sensation, ml | 392.6 ± 110.6 | 423.3 ± 100.7 | -0.3 (-1.0; 0.4) | -0.1 (-0.2; 0.1)
Walsh, 2001 ^572^ | Neuromodulation therapy: Antidromic transcutaneous sacral neurostimulation during the second fill of standard urodynamic filling cystometry with 10Hz frequency, a pulse width of 200 milliseconds in continuous mode at the maximum tolerable level. | Control group underwent a second fill of standard urodynamic filling cystometry without neurostimulation | FDV, infused bladder volume (ml) at first desire to void | 167.2 ± 97.2 | 114.2 ± 90.8 | 0.6 (0.2; 0.9) | 0.5 (0.2; 0.8)
N = 146 | | | SDV, infused bladder volume at perceived strong desire to void | 247.4 ± 110.1 | 193.7 ± 156.1 | 0.4 (0.1; 0.7) | 0.2 (0.0; 0.4)
76% female | | | Urge, infused bladder volume at sensation of urgency; | 331.5 ± 136.8 | 255.4 ± 96.7 | 0.6 (0.3; 1.0) | 0.3 (0.1; 0.4)
| | | CMax, maximum infused cystometric capacity. | 404.2 ± 229.7 | 315.9 ± 194.3 | 0.4 (0.1; 0.7) | 0.1 (0.0; 0.2)
Yamanishi, 2000 ^548^ | Electrical stimulation 15 minutes twice daily for 4 weeks (vaginal electrode in women and an anal or surface electrode in men to provide alternating pulses of 10Hz square waves of 1msec pulse duration and a maximum output current of 60mA). | Sham inactive device | Bladder capacity at first desire to void (ml) | 174.2 ± 83.1 | 130.0 ± 69.9 | 0.6 (0.1; 1.1) | 0.4 (0.1; 0.8)
N = 68 | | | Maximum cystometric capacity (ml) | 285.0 ± 143.4 | 182.9 ± 99.0 | 0.8 (0.3; 1.3) | 0.4 (0.2; 0.7)
57% female | | | Detrusor pressure at maximum sensation (cm/H2O) | 34.6 ± 12.5 | 34.8 ± 13.6 | 0.0 (-0.5; 0.5) | 0.0 (-1.4; 1.3)
| | | Amplitude of Detrusor overactivity (cm/H2O) | 39.1 ± 36.6 | 50.9 ± 29.8 | -0.4 (-0.8; 0.1) | -0.7 (-1.6; 0.3)
| | | Bladder compliance at maximum sensation (ml/cm/H2O) | 27.8 ± 24.1 | 31.6 ± 35.7 | -0.1 (-0.6; 0.4) | -0.4 (-1.9; 1.1)
Yamanishi, 2000 ^549^ | Functional magnetic stimulation applied continuously at 10Hz | Functional electrical stimulation applied continuously at 10 Hz with vaginal electrode in women and a surface electrode on the dorsal part of the penis in men | Bladder capacity at first desire to void (ml) | 225.1 ± 123.7 | 220.4 ± 110.9 | 0.0 (-0.7; 0.7) | 0.0 (-0.3; 0.3)
N = 32 | | | Bladder compliance at maximum sensation (ml/cm/H2O) | 32.7 ± 25.6 | 24.3 ± 18.3 | 0.4 (-0.3; 1.1) | 1.6 (-1.3; 4.5)
54% female | | | Amplitude of Detrusor overactive contraction (cm/H2O) | 51.5 ± 48.2 | 51.3 ± 36.9 | 0.0 (-0.7; 0.7) | 0.0 (-1.3; 1.4)
| | | Maximum cystometric capacity (ml) | 290.5 ± 146.3 | 266.9 ± 151.0 | 0.2 (-0.5; 0.9) | 0.1 (-0.2; 0.3)
| | | Detrusor pressure at maximum capacity (cm/H2O) | 13.9 ± 15.4 | 15.4 ± 10.5 | -0.1 (-0.8; 0.6) | -0.7 (-5.3; 3.8)

Bold- significant differences in outcomes at 95% confidence level

Table F110 Effects of devices on risk and progression of incontinence in females

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Nygaard, 1995 ^576^ | 20 female exercisers ages 33–73 with urinary incontinence during exercise and positive coughing test. | 1 40-minute standardized aerobics session wearing a Hodge pessary with support; 2 40-minute standardized aerobics sessions wearing a super tampon; 3 40-minute standardized aerobics sessions with no mechanical device | Urine loss as change in the weight of the pad during exercising. | No intention to treat. Open label.
Crossover RCT to examine the effects of Hodge pessary with support, a super tampon on urinary incontinence during exercise. | Exclusion criteria: Prolapse of the uterus, stenotic vagina, or pelvic mass. | | Continence-pad weight gain <4g | Block randomization.
Duration: three exercise sessions. | Loss of followup: 10% | | | Allocation concealment not reported. Baseline data not reported.
| | | | Sample size not justified.
Thyssen, 2001 ^577^ | 94 women with the predominant symptom of stress incontinence, 39 were recruited in Denmark, 28 in England, and 27 in Australia. | 1 Conveen Continence Guard, CCG made of hydrophilic polyurethane and requires soaking in water before being placed on a handle like applicator for insertion.; 2 Contrelle Continence Tampon, CCT, coloplastis made of hydrophobic polyurethane and supplied ready-assembled within an applicator, allowing insertion directly into the vagina with no manual contact. | 24 hour pad test, uroflowmetry, postvoid residual urine volume and a voiding diary | No intention to treat. Open label.
Crossover RCT to examine the effects of disposable intravaginal device on stress incontinence in women. | Exclusion criteria: Major uterovaginal prolapse. | | | Block randomization.
Duration: 5 weeks | Loss of followup: 34% | | | Allocation concealment not reported. Baseline data not reported.
| | | | Sample size not justified.
Seo, 2004 ^578^ | 120 patients, who required a non-surgical treatment for urinary incontinence. | 1 Pelvic floor exercise (5 second contraction and 10 second relaxation, 3–5 times for >5 minutes/day) and functional electrical stimulation biofeedback (35Hz–50Hz for 24 seconds); 2 training sessions /week.; 2 Vaginal cone, 150g dumbbell-shaped made of fine ceramic material. | Self reported urinary incontinence. | Intention to treat not stated. Open label.
RCT to examine the effects of vaginal cone with conventional FES-biofeedback therapy for female urinary incontinence. | Exclusion criteria: not reported. | | Urodynamic outcomes. | Randomization and allocation concealment not reported. Baseline data not reported.
Duration: 6 weeks | Loss of followup: not reported. | | | Sample size not justified.
Robinson, 2003 ^579^ | 24 women 30–75 years old with mixed or stress urinary incontinence >2 episodes/week >2g urine loss on baseline pad weight test, with sound mental condition, willing to use >3 devices/week. | 1 Urethral device (NEAT) - sterile urethral insert with disposable applicator packaged with device.; 2 Reliance insert sterile balloon type device | Success was defined as a 50% or greater reduction in urine loss using the formula 100 [(pad weight without device -pad weight with device)/pad weight with device]. | No Intention to treat. Single blind. randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine the effects of new urethral device or the reliance insert on female urinary incontinence. | Exclusion criteria: overflow incontinence or neurogenic bladder, type III incontinence, kidney inflammatory diseases, urinary tract infection, use of anticoagulants or incontinence medications, allergy to antibiotics, diabetes mellitus type II, pregnancy, urethral mucosal abnormalities, prosthetic heart valve, HRT last 3 months, collagen injections or other urethral bulking agents last 3 months, detrusor contraction >20cm/H20. | | Pure stress incontinence-urine loss with no detrusor contractions >15cm/H20 in any point before cystometric bladder capacity achieved. | Sample size not justified.
Duration of followup: 4 months | Loss of followup: 33.3 % | | Mixed urinary incontinence- urine loss with detrusor contractions at 16–20cm/H20 in any point before cystometric bladder capacity achieved.
Bo,1999 ^513^ | 107 women with clinically and urodynamically proved genuine stress incontinence >4g of leakage measured by pad test with standardized bladder volume. | 1 Pelvic floor exercise with 8–12 contractions 3 times/day in groups with skilled physical therapists 1/week.; 2 Electrical stimulation using vaginal intermittent stimulation with MS 106 Twin at 50Hz 30 minutes/day.; 3 Vaginal cones of 20, 40, and 70g for 20 minutes/day.; 4 Untreated control group offered use of a continence guard | Muscle strength measured by vaginal squeeze pressure 1/month. Pad test with standardized bladder volume. 24 hour pad test. Self reported symptoms of severity. Leakage index. Patients indicated on a 5 point scale (5 always, 4 often, 3 sometimes, 2 seldom, 1 never) the frequency of urinary leakage during sneezing, coughing, laughing, walking, walking downhill, running, jumping, and lifting. The mean was calculated as an index of leakage frequency before and after treatment. | Intention to treat.
RCT to examine the effects of pelvic floor exercises, electrical stimulation, vaginal cones, and no treatment on females' genuine stress incontinence. | Exclusion criteria: Urinary incontinence other than genuine stress incontinence, involuntary detrusor contractions >10cm/H2O on cystometry, abnormal bladder function (residual urine >0ml and maximal uroflow <15 ml/s), previous surgery for genuine stress incontinence, neurological or psychiatric disease, ongoing urinary tract infections, other diseases that could interfere with participation, use of concomitant treatments during the trial, and inability to understand instructions given in Norwegian. | | Objective cure as <2g leakage on the pad test with standardized bladder volume. Subjective cure as (number of women stating that the condition was “unproblematic” after treatment). | Single blind.
Duration: 6 months | Loss of followup: 12.3% | | | Computer generated random numbers stratified by baseline leakage. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Nielsen, 1993 ^580^ | 40 women with genuine urinary stress incontinence. | 1 Urethral plug as oval metal plate, a soft stalk, and 1 sphere along the stalk with fixed distances between the metal plate and the spheres. Inside the stalk is a removable semi-rigid guide pin to ease insertion.; 2 Urethral plug as oval metal plate, a soft stalk, and 2 spheres along the stalk with fixed distances between the metal plate and the spheres. Inside the stalk is a removable semi-rigid guide pin to ease insertion. | Self reported urinary incontinence. Pad weighting test. | No intention to treat. Open label.
Cross-sectional | Exclusion criteria: not reported | | | Randomization and allocation concealment not reported. Baseline data not reported.
RCT to examine effects of urethral plug on female genuine urinary stress incontinence. | Loss of followup: 55% | | | Sample size not justified.
Duration: 2 weeks

Table F111 Effects of medical devices on female urinary incontinence (events rate)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Nygaard, 1995 ^576^ | 40 minute standardized aerobics sessions wearing a Hodge pessary with support | 40 minute standardized aerobics sessions wearing a super tampon | Continent during exercise | 7 | 12 | 36.0 | 58.0 | 0.6 (0.3; 1.2)
N = 20
Thyssen, 2001 ^577^ | Conveen continence disposable intravaginal device guard, CCG made of hydrophilic polyurethane requires soaking in water before being placed on a handle like applicator for insertion | Contrelle Continence Tampon, CCT, coloplastic made of hydrophobic polyurethane and supplied readyassembled within an applicator, allowing insertion directly into the vagina with no manual contact | Cured from stress urinary incontinence | 34 | 45 | 36.0 | 48.0 | 0.8 (0.5; 1.1)
N = 94 | | | Self reported Improvement in stress urinary incontinence | 38 | 34 | 40.0 | 36.0 | 1.1 (0.8; 1.6)
Seo, 2004 ^578^ | Pelvic floor exercise (5 second contraction and 10 second relaxation, 3–5 times for >5 minutes/day) and functional electrical stimulation biofeedback (35Hz–50Hz for 24 seconds); 2 training sessions/week | Vaginal cone, 150g dumbbell-shaped made of fine ceramic material | Self reported improvement in urinary incontinence | 55 | 53 | 91.7 | 88.3 | 1.0 (0.9; 1.2)
N = 120
Robinson, 2003 ^579^ | Urethral device (NEAT) sterile urethral insert with disposable applicator packaged with device | Reliance insert sterile balloon type device | Success as a 50% or greater reduction in urine loss | 9 | 6 | 67.0 | 58.0 | 1.3 (0.7; 2.4)
N = 24 | | | Success as negative pad weight test | 9 | 7 | 73.0 | 62.0 | 1.1 (0.6; 1.9)
Bo, 1999 ^513^ | Vaginal cones of 20, 40, and 70g for 20 minutes/day | Untreated control group offered use of a continence guard | Objective cure as <2g leakage on pad test with standardized bladder volume | 4 | 2 | 13.8 | 6.3 | 2.2 (0.4; 11.2)
N = 122 | | | Subjective cure as (number of women stating that condition was “unproblematic” after treatment) | 2 | 1 | 6.9 | 3.1 | 2.2 (0.2; 23.1)
| | | Urinary continence and almost continent | 5 | 1 | 17.2 | 3.1 | 5.5 (0.7; 44.5)

Table F112 Effects of medical devices on self reported severity of urinary incontinence, quality of life, and objective instrumental measures of severity (continuous variables)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Self reported severity of urinary incontinence
Bo, 1999 ^513^ | Vaginal cones of 20, 40, and 70g for 20 minutes/day. | Untreated control group offered use of a continence guard | Change from baseline in episodes of leakage in 3 days | 0.8 ± 5.3 | 0.3 ± 2.3 | 0.1 (-0.4; 0.6) | 41.5 (-126.2; 209.2)
N = 122
Seo, 2004 ^578^ | Pelvic floor exercise (5 second contraction and 10 second relaxation, 3–5 times for >5 minutes/day) and functional electrical stimulation biofeedback (35Hz–50Hz for 24 seconds); 2 training sessions/ week | Vaginal cone,150g dumbbellshaped made of fine ceramic material | Changes in episodes of urine leakage | -1.1 ± 0.2 | -0.6 ± 0.2 | -2.3 (-2.8; -1.9) | 369.8 (443.6; 296.0)
N = 120 | | | Changes in amount of urine leakage | -0.6 ± 0.2 | -0.6 ± 0.2 | 0.0 (-0.4; 0.4) | 0.0 (56.8; -56.8)
Self reported quality of life
Seo, 2004 ^578^ | Pelvic floor exercise (5 second contraction and 10 second relaxation, 3–5 times for >5 minutes/day) and functional electrical stimulation biofeedback (35Hz–50Hz for 24 seconds); 2 training sessions/week | Vaginal cone,150g dumbbellshaped made of fine ceramic material | Changes in scores: restriction in exercise due to incontinence | -0.6 ± 0.2 | -0.4 ± 0.2 | -1.3 (-1.7; -0.9) | 364.9 (474.7; 255.2)
N = 120 | | | Changes in scores: avoiding places due to urinary incontinence | -0.3 ± 0.1 | -0.1 ± 0.2 | -1.1 (-1.5; -0.7) | 848.3 (1,144.1; 552.5)
Bo, 1999 ^513^ | Vaginal cones of 20, 40, and 70g for 20 minutes/day. | Untreated control group offered use of a continence guard | Change from baseline in leakage index | -0.3 ± 0.5 | 0.1 ± 0.6 | -0.7 (-1.2; -0.2) | -720.2 (-1,239.2; -201.2)
N = 122 | | | Change from baseline in social activity index | 0.1 ± 1.1 | -0.2 ± 1.7 | 0.2 (-0.3; 0.7) | -103.3 (148.7; -355.2)
Effects of medical devices on objective measured severity of urinary incontinence
Nygaard, 1995 ^576^ | 40 minute standardized aerobics sessions wearing a Hodge pessary with support | 40 minute standardized aerobics sessions with no mechanical device | Mean urine loss as change in weight of the pad during exercising. | 36.4 ± 67.1 | 45.3 ± 45.7 | -0.2 (-0.8; 0.5) | -0.3 (-1.7; 1.0)
N = 20 | 40 minute standardized aerobics sessions wearing a super tampon | | | 31.0 ± 46.2 | 45.3 ± 45.7 | -0.3 (-0.9; 0.3) | -0.7 (-2.1; 0.7)
Thyssen ^577^ | Conveen continence disposable intravaginal device guard, CCG made of hydrophilic polyurethane requires soaking in water before being placed on a handle like applicator for insertion | No device | 24 hour pad test (g) | 20.2 ± 12.8 | 43.1 ± 11.0 | -1.9 (-2.3; -1.6) | -4.5 (-5.3; -3.6)
| Contrelle continence disposable intravaginal device tampon, CCT, coloplastic made of hydrophobic polyurethane and supplied readyassembled within an applicator, allowing insertion directly into the vagina with no manual contact | | 24 hour pad test (g) | 10.8 ± 5.4 | 43.1 ± 11.0 | -3.7 (-4.2; -3.3) | -8.6 (-9.8; -7.5)
Seo, 2004 ^578^ | Pelvic floor exercise (5 second contraction and 10 second relaxation, 3–5 times for >5 minutes/day) and functional electrical stimulation biofeedback (35Hz–50Hz for 24 seconds); 2 training sessions/week | Vaginal cone, 150g dumbbellshaped made of fine ceramic material | Pad test | 3.4 ± 5.4 | 3.7 ± 6.7 | -0.1 (-0.4; 0.3) | -1.5 (-11.1; 8.1)
N = 120
Nielsen, 1993 ^580^ | Urethral plug as oval metal plate, a soft stalk, and 1 sphere along the stalk with fixed distances between the metal plate and the spheres. Inside the stalk is a removable semi-rigid guide pin to ease insertion | Urethral plug as oval metal plate, a soft stalk and 2- spheres along the stalk with fixed distances between the metal plate and the spheres. Inside the stalk is a removable semi-rigid guide pin to ease insertion. | Urine leakage during pad weighting test. | 6.0 ± 76.7 | 3.0 ± 80.0 | 0.0 (-0.4; 0.5) | 1.3 (-13.3; 15.9)
N = 40
Bo, 1999 ^513^ | Vaginal cones of 20, 40, and 70g for 20 minutes/day | Untreated control group offered the use of a continence guard | Change from baseline in stress pad test (g) | -14.7 ± 34.2 | -12.7 ± 41.8 | -0.1 (-0.6; 0.5) | 0.4 (4.4; -3.5)
N = 122 | | | Change from baseline in 24 hour pad test (g) | -22.0 ± 89.3 | -7.1 ± 37.8 | -0.2 (-0.7; 0.3) | 3.1 (10.2; -4.0)
Effects of medical devices on urodynamic outcomes
Thyssen, 2001 ^577^ | Conveen continence disposable intravaginal device guard, CCG made of hydrophilic polyurethane requires soaking in water before being placed on a handle like applicator for insertion | No device | Peak flow, ml/s | 25.8 ± 22.8 | 25.9 ± 28.7 | 0.0 (-0.3; 0.3) | 0.0 (-1.1; 1.1)
N = 94 | | | Voided volume, ml | 216.0 ± 256.0 | 251.0 ± 263.3 | -0.1 (-0.4; 0.2) | -0.1 (-0.2; 0.1)
| | | Corrected peak flow, ml/s | 1.9 ± 2.8 | 1.8 ± 1.4 | 0.0 (-0.2; 0.3) | 2.5 (-13.4; 18.4)
| | | Residual urine, ml | 17.1 ± 74.6 | 18.3 ± 81.1 | 0.0 (-0.3; 0.3) | -0.1 (-1.6; 1.5)
| Contrelle continence disposable Intravaginal device tampon, CCT, coloplastic made of hydrophobic polyurethane and supplied ready-assembled within an applicator, allowing insertion directly into the vagina with no manual contact | No device | Peak flow, ml/s | 24.3 ± 24.5 | 25.9 ± 28.7 | -0.1 (-0.3; 0.2) | -0.2 (-1.3; 0.9)
| | | Voided volume, ml | 215.0 ± 243.3 | 251.0 ± 263.3 | -0.1 (-0.4; 0.1) | -0.1 (-0.2; 0.1)
| | | Corrected peak flow, ml/s | 2.1 ± 2.3 | 1.8 ± 1.4 | 0.2 (-0.1; 0.4) | 8.8 (-7.1; 24.8)
| | | Residual urine, ml | 13.2 ± 55.9 | 18.3 ± 81.1 | -0.1 (-0.4; 0.2) | -0.4 (-2.0; 1.2)
Seo, 2004 ^578^ | Pelvic floor exercise (5 second contraction and 10 second relaxation, 3–5 times for >5 minutes/day) and functional electrical stimulation biofeedback (35Hz–50Hz for 24 seconds); 2 training sessions/week | Vaginal cone,150g dumbbellshaped made of fine ceramic material | Maximum urethral closing pressure, mm/H20 | 77.9 ± 31.0 | 78.4 ± 18.3 | 0.0 (-0.4; 0.3) | 0.0 (-0.5; 0.4)
N = 120 | | | Maximum vaginal pressure, mmHg | 33.6 ± 16.7 | 27.2 ± 13.2 | 0.4 (0.1; 0.8) | 1.6 (0.2; 2.9)
| | | Duration of PEM contractions, seconds | 10.2 ± 5.7 | 9.3 ± 5.4 | 0.2 (-0.2; 0.5) | 1.8 (-2.1; 5.7)
Bo, 1999 ^513^ | Vaginal cones of 20, 40, and 70g for 20 minutes/day. | Untreated control group offered use of a continence guard | Change in strength of pelvic floor muscle | 15.4 ± 12.4 | 16.0 ± 4.2 | -0.1 (-0.6; 0.4) | -0.4 (-3.6; 2.7)
N = 122

Bold- significant differences in outcomes at 95% confidence level

Table F113 Effects of medical devices on urinary incontinence in community-dwelling males

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Chancellor, 1999 ^581^ | 57 men with spinal cord injury and electromyographic and manometric evidence of external detrusor-sphincter dyssynergia during involuntary detrusor contractions. | 1 UroLume sphincteric stent (2, 2.5, or 3cm) prosthesis inserted using a 22F cystoscopic insertion tool with distal end of the prosthesis extended at least 5mm into the bulbous urethra and well beyond the distal aspect of the external sphincter.; 2 Conventional external sphincterotomy. | Urodynamic outcomes. Self reported changes in urinary incontinence. | No Intention to treat. Open label
RCT to examine effects of sphincteric stent or external sphincterotomy on urinary incontinence in spinal cord injured men. | Exclusion criteria: Concomitant documented bladder neck or prostatic obstruction | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 24 months | Loss of followup: 42.5% | | | Sample size not justified
Moore, 2004 ^582^ | 12 men, 6 months after radical prostatectomy with stress urinary incontinence requiring continuous incontinence pad protection, normal perineal and penile sensation, intact penile skin, and the ability to read and speak English. | Penile Compression Devices:; 1 C3 penile compression device with 2 styrofoam arms with a raised bottom arm applies pressure on the urethra.; 2 Cunningham clamp; 3 U-tex male adjustable tension nylon band with a urethral occlusion pad and nylon strap adjustable for comfort and continence. | 4 hour pad test weight gain of 2g or more in one pad was considered urinary incontinence | Intention to treat not stated. Open label. Computer-generated randomization with random number table. Allocation concealment not adequate. Sample size justified.
Cross-over RCT to examine effects of penile compression devices on male urinary incontinence. | Exclusion criteria: Neurologic or cognitive impairment (Mini-Mental State Examination score <27), neurologic disorders that could affect sensation or peripheral circulation, sufficient manual dexterity to manage the penile compression device, previous radiotherapy, symptoms of overactive bladder.
Acute test.

Table F114 Clinical improvement in urinary incontinence in 57 males after inserted sphincter stent

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI)
Sample
Chancellor, 1999 ^581^ | UroLume sphincteric stent (2, 2.5, or 3cm) prosthesis inserted using a 22F cystoscopic insertion tool with distal end of prosthesis extended at least 5mm. into the bulbous urethra and well beyond the distal aspect of the external sphincter | Conventional external sphincterotomy | Significant improvement in bladder emptying ability | 12 | 6 | 38.7 | 23.1 | 1.7 (0.7; 3.8) | -6 (16; -2)
N = 57

Table F115 Effects of devices on urinary incontinence in males (severity measures)

Author | Outcome | Active Treatment | Control Treatment | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Chancellor, 1999 ^581^ | Mean maximum. detrusor. Cm/H20 | UroLume sphincteric stent (2, 2.5, or 3cm) prosthesis inserted using a 22F cystoscopic insertion tool with distal end of prosthesis extended at least 5mm. into the bulbous urethra and well beyond the distal aspect of the external sphincter | Conventional external sphincterotomy | 71.6 ± 43.8 | 41.6 ± 16.3 | 0.9 (0.3; 1.4) | 2.1 (0.8; 3.4)
N = 57 | Mean residual urine, ml | | | 132.0 ± 159.0 | 112.0 ± 106.0 | 0.1 (-0.4; 0.7) | 0.1 (-0.3; 0.6)
| Mean cystometric capacity, ml | | | 262.0 ± 134.0 | 220.0 ± 135.0 | 0.3 (-0.2; 0.8) | 0.1 (-0.1; 0.4)
Moore, 2004 ^582^ | 4 hour pad test: mean urine loss | U-tex male adjustable tension | Cunningham clamp | 53.3 ± 65.7 | 17.1 ± 21.3 | 0.7 (-0.1; 1.6) | 4.3 (-0.5; 9.2)
N = 12 | | C3 penile compression device with 2 styrofoam arms with a raised bottom arm applies pressure on the urethra | | 32.3 ± 24.3 | 17.1 ± 21.3 | 0.7 (-0.2; 1.5) | 3.9 (-0.9; 8.7)
| Mean right resistance index | Cunningham clamp | No device | 0.9 ± 0.1 | 0.9 ± 0.1 | 0.2 (-0.6; 1.0) | 19.2 (-69.9; 108.2)
| Mean left resistance index | | | 0.9 ± 0.3 | 0.9 ± 0.1 | 0.0 (-0.8; 0.8) | -5.3 (-97.3; 86.7)
| Mean right resistance index | C3 penile compression device with 2 styrofoam arms with a raised bottom arm applies pressure on the urethra | No device | 0.9 ± 0.1 | 0.9 ± 0.1 | 0.2 (-0.6; 1.0) | 22.2 (-66.9; 111.4)
| Mean left resistance index | | | 0.9 ± 0.1 | 0.9 ± 0.1 | 0.5 (-0.3; 1.3) | 54.7 (-38.7; 148.1)
| Mean right resistance index | U-tex male adjustable tension | No device | 0.9 ± 0.1 | 0.9 ± 0.1 | 0.3 (-0.5; 1.1) | 36.8 (-52.8; 126.4)
| Mean left resistance index | | | 0.9 ± 0.1 | 0.9 ± 0.1 | 0.4 (-0.4; 1.2) | 43.7 (-49.1; 136.6)

Table F116 Effects of bulking agents and transurethral radiofrequency energy collagen micro-remodeling on urinary incontinence in females

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Corcos, 2005 ^583^ | 133 women older than 30 years with stress urinary incontinence lasted for >6 months. | 1 Intraurethral collagen submucosal injection 4 injections at 1-month intervals; 2 Surgery (needle bladder neck suspensions, Burch, and slings). The choice of technique was left to the surgeon. | Success as dry 24 hour pad test (<2.5g). Symptoms of incontinence, general QOL, disease-specific QOL | Intention to treat.
Noninferiority RCT to examine effects of collagen injection or surgery on female stress urinary incontinence. | Exclusion criteria: Contraindications to surgery or collagen injections (allergic reaction), associated conditions (e.g., severe medical disease or indication for hysterectomy) or pelvic prolapse (vault, cystocele, rectocele), neurogenic bladder or interstitial cystitis or a history of pelvic radiation or previous treatment by collagen injection. | | | Centralized randomization stratified by center with randomly distributed blocks 4 and 6 in size.
Duration of followup: 12 months | Loss of followup: 3.7% | | | Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Bano, 2005 ^584^ | 50 women with urodynamically proven stress incontinence. | 1 Peri or transurethral porcine dermal implant injection (Permacol); 2 Transurethral silicone injection (Macroplastique) | International Continence Society (ICS) standard 1 hour pad test. Self reported incontinence using Stamey scoring system and Kings College Hospital Quality of Health Questionnaire (KCQ) | No Intention to treat. Open label.
RCT to examine effects of porcine dermal implant (Permacol) and silicone injection (Macroplastique) on urodynamic stress incontinence in females. | Exclusion criteria: not reported. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 6 months | Loss of followup: 2% | | | Sample size not justified.
Schulz, 2004 ^585^ | 40 women ages 18–80 years old, with genuine stress incontinence for >12 months, or mixed incontinence with a minor and controlled urge component, who failed 3 months conservative treatments. | 1 Periurethral route of injection of bulking agent-dextran copolymer; 2 Transurethral route of injection of bulking agent-dextran copolymer | Urinary continence as 100% improvement in self reported symptoms, no leakage episodes and negative pad test | Intention to treat.
RCT to examine effects of periurethral and transurethral injections of bulking agents on stress urinary incontinence in females. | Exclusion criteria: Other treatments for incontinence, urinary tract infection, bladder capacity <250ml or postvoid residual volume >100ml, neurogenic bladder, grade 3 cystoele, uterine prolapse or rectocele, radiation of urethra, pregnancy, life expectancy <15 months. | | | Open label.
Duration of followup: 12 months | Loss of followup: 15% | | | Computer generated block randomization scheme. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Lightner, 2001 ^586^ | 355 women diagnosed with stress urinary incontinence due to intrinsic sphincter deficiency, abdominal leak point pressure of less than 90cm/H2O, who failed prior surgical and medical treatment. | 1 Injection of bulking agent 1.0ml durasphere maximum 5 times with a minimum 7 day interval.; 2 Injection of bulking agent bovine collagen maximum 5 times with a minimum 7 day interval. | Self reported urinary incontinence with grade 0 (dry) to grade 3 (continuous) urinary leakage | No Intention to treat. Double blind.
RCT to examine effects of bulking agents on stress urinary incontinence due to intrinsic sphincter deficiency in women. | Exclusion criteria: Prior injections of any urethral bulking agents, positive intradermal test injections of bovine collagen and beta-glucan | | | Randomization and allocation concealment not reported. Baseline data not reported.
Duration of followup: 12 months | Loss of followup: 38% | | | Sample size not justified.
Appell, 2006 ^587^ | 173 women with stress urinary incontinence, bladder outlet hypermobility, and leak point pressure >60cm/H2O. | 1 Transurethral radiofrequency energy collagen micro-remodeling; 2 Sham treatment probes lacked needle electrodes and sham treatment of radiofrequency generator | Self reported improvement in urinary incontinence as 25% reduction in both incontinence episode frequency and stress pad weight. Impact on subject quality of life as incidence of >10 point improvement on the Incontinence Quality of Life (IQOL) score. A baseline I-QOL score of 0–30 points - “severe SUI,” 31–60 points - “moderate SUI,” and 61–90 points - “mild SUI.” | No intention to treat. Single blind.
Placebo controlled | Exclusion criteria: Evidence of detrusor overactivity on cystometrogram, post-void residual bladder volumes >50cc, significant pelvic organ prolapse (POP-QStage IV) on physical examination, history of dry or wet overactive bladder, previous surgical or bulking agent therapy, abnormal urinalyses, positive urine cultures, and positive pregnancy test. | | | Computer generated randomization with ratio 2:1. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine effects of transurethral radiofrequency energy collagen micro-remodeling on female stress urinary incontinence. | Loss of followup: 18% | | | Sample size justified.
Duration of followup: 12 months
Lee, 2001 ^588^ | 68 women with stress urinary incontinence determined by history, urinary leakage via the urethra with cough provocation. | 1 Periurethral injections of autologous fat (30cc of fat from the anterior abdominal wall or buttock through a single 2–3mm) with 3 maximum injections depending on outcomes measures.; 2 Placebo (saline). | Cure from urinary incontinence as no leakage on the 1 hour pad test, no leakage seen from the urethra with coughing and a continence questionnaire score of 0. Improvement was defined as a decrease in the continence questionnaire score of 5 points or greater. | No Intention to treat. Double blind.
Placebo controlled | Exclusion criteria: Detrusor instability on multichannel urodynamic, co-interventions, including hormone replacement, weight reduction, or Kegel exercises, other diagnoses causing incontinence, including bladder instability. | | | Computerized randomization with random number tables. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine effects of periurethral autologous fat injection on female stress urinary incontinence. | Loss of followup: 19% | | | Sample size justified.
Duration of followup: 24 months
Strasser, 2007 ^589^ | 63 females 36–84 years old with intrinsic sphincter insufficiency or stress urinary incontinence with only mild hypermobility of the urethra and the urinary bladder; good state of health who failed pelvic floor muscle exercises. | 1 Transurethral ultrasonography-guided injections of autologous myoblasts and fibroblasts; regular training of the rhabdosphincter for 12 weeks and trans vaginal electrical stimulation for 4 weeks.; 1 Conventional endoscopic injections of collagen; regular training of the rhabdosphincter for 12 weeks and trans vaginal electrical stimulation for 4 weeks | 24-hour voiding diary with incontinence score (range 0–6): 0 representing continence; 6 representing complete incontinence. 24-hour pad test. | Intention to treat.
RCT to examine the effects of ultrasonography-guided injections of autologous cells or endoscopic injections of collagen on stress urinary incontinence. | Exclusion criteria: urge incontinence and pronounced hypermobility of the urethra. | | Quality of life questionnaire with possible scores from 22 (severely restricted quality of life) to 110 (no restrictions on quality of life). | Single blind.
Duration of followup: 12 months | Loss of follow up -none | | | Computer-generated randomization list with permuted blocks and ratio of 2:1. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.

Table F117 Effects of bulking agents and transurethral radiofrequency energy collagen micro-remodeling on urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Active Cases | Number of Control Cases | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Corcos, 2005 ^583^ | Intraurethral collagen sub mucosal injection | Surgery (needle bladder neck suspension, Burch, and slings) | Success as dry 24 hour pad test (<2.5g) | 34 | 37 | 51.5 | 55.2 | 0.9 (0.7; 1.3)
N = 133 | | | Complete retention | 1 | 9 | 1.5 | 13.4 | 0.1 (0.0; 0.9) | 8.4 (8; 55) | 119 (18; 132)A
Bano, 2005 ^584^ | Peri or transurethral porcine dermal implant injection (Permacol) | Transureth ral silicone injection (Macroplas tique | Urinary continence (negative pad test) | 15 | 9 | 60.0 | 36.0 | 1.7 (0.9; 3.1)
N = 50 | | | Improvement in urinary incontinence (pad test) | 15 | 10 | 60.0 | 40.0 | 1.5 (0.8; 2.7)
| | | Improved urinary incontinence scores (Stamey) | 14 | 10 | 56.0 | 40.0 | 1.4 (0.8; 2.5)
| | | Improved urinary incontinence scores (Kings College Hospital Quality of Health Questionnaire) | 14 | 7 | 56.0 | 28.0 | 2.0 (1.0; 4.1)
Schulz, 2004 ^585^ | Periurethral route of injection of bulking agent-dextran copolymer | Transureth ral route of injection of bulking agent-dextran copolymer | Objective urinary continence (dry in pad test) | 1 | 3 | 5.0 | 15.0 | 0.3 (0.0; 2.9)
N = 40 | | | Subjective improvement in urinary incontinence | 6 | 7 | 30.0 | 35.0 | 0.9 (0.3; 2.1)
Lightner, 2001 ^586^ | Injection of bulking agent 1.0ml | Injection of bulking agent bovine collagen maximum 5 times with a minimum 7-day interval | Improvement of 1 or more continence grades | 76 | 79 | 43.2 | 42.0 | 1.0 (0.8; 1.3)
N = 355 | Durasphere maximum 5 times with a minimum 7-day interval | | Incidence of urgency | 43 | 22 | 24.7 | 11.9 | 2.1 (1.3; 3.3) | 7.8 (4; 28) | 128 (36; 279)E
Appell, 2006 ^587^ | Transurethral radiofrequency energy collagen micro-remodeling | Sham treatment | Improvement >10 point I-QOL score | 53 | 28 | 48.0 | 44.0 | 1.1 (0.8; 1.5)
N = 173
Lee, 2001 ^588^ | Periurethral injections of autologous fat (30cc of fat from the anterior abdominal wall or buttock through a single 2–3mm) with 3 maximum injections depending on outcome measures. | Placebo (saline) | Cured or improved | 6 | 6 | 17.1 | 18.2 | 0.9 (0.3; 2.6)
N = 68
Strasser, 2007 ^589^ | Transurethral ultrasonograp hy-guided injections of autologous myoblasts and fibroblasts; regular training of the rhabdosphinct er for 12 weeks and trans vaginal electrical stimulation for 4 weeks | Convention al endoscopic injections of collagen; regular training of the rhabdosphi ncter for 12 weeks and trans vaginal electrical stimulation for 4 weeks | Continence | 38 | 2 | 90.48 | 9.50 | 9.50 (2.53; 35.63) | 1 (0; 7) | 810 (146; 3,298)E
N = 63 | | | Substantial improvement in urinary incontinence | 3 | 1 | 7.14 | 4.76 | 1.50 (0.17; 13.56)
Followup: 12 months 100% female | | | Slight improvement in urinary incontinence | 1 | 6 | 2.38 | 28.57 | 0.08 (0.01; 0.65) | 4 (4; 10) | 262 (101; 283)A
| | | Number of incontinent patients | 4 | 19 | 9.52 | 90.48 | 0.11 (0.04; 0.27) | 1 (1; 2) | 810 (660; 868)A

Bold- significant differences in outcomes at 95% confidence level

Table F118 Effects of bulking agents and transurethral radiofrequency energy collagen micro-remodeling on severity of urinary incontinence

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95 %CI)
Urodynamic outcomes
Appell, 2006 ^587^ | Transurethral radiofrequency energy collagen micro-remodeling | Sham treatment | Change in leak point pressure | 13.2 ± 39.2 | -2.0 ± 33.8 | 0.4 (0.1; 0.7) | -20.4 (-4.7; -36.0)
N = 173
Lee, 2001 ^588^ | Periurethral injections of autologous fat (30cc of fat from the anterior abdominal wall or buttock through a single 2–3mm) with 3 maximum injections depending on outcomes measures. | Placebo (saline). | Mean maximum. urethral closure pressure | 37.0 ± 18.1 | 35.6 ± 24.2 | 0.1 (-0.4; 0.5) | 0.2 (-1.2; 1.5)
N = 68 | | | Mean leak point pressure (cm/H2O) | 101.4 ±27.9 | 76.5 ± 27.9 | 0.9 (0.4; 1.4) | 1.2 (0.5; 1.8)
Pad weight test
Lightner, 2001 ^586^ | Injection of bulking agent 1.0ml durasphere maximum 5 times with a minimum 7 day interval | Injection of bulking agent bovine collagen maximum 5 times with a minimum 7 day interval | Urine loss as measured by mean change in pad weight test | 27.9 ± 43.6 | 26.4 ± 63.7 | 0.0 (-0.2; 0.2) | 0.1 (-0.7; 0.9)
N = 355
Lee, 2001 ^588^ | Periurethral injections of autologous fat (30cc of fat from the anterior abdominal wall or buttock through a single 2–3mm) with 3 maximum injections depending on outcomes measures. | Placebo (saline) | Mean pad weight (gm) | 14.8 ± 20.1 | 18.5 ± 27.6 | -0.2 (-0.6; 0.3) | -0.8 (-3.4; 1.7)
N = 68
Quality of life
Corcos, 2005 ^583^ | Intraurethral collagen sub mucosal injection | Surgery (needle bladder neck suspensions, Burch, and slings) | Physical functioning | 75.7 ± 59.3 | 73.8 ± 75.3 | 0.0 (-0.3; 0.4) | 0.0 (-0.4; 0.5)
N = 133 | | | Role physical | 68.1 ± 85.9 | 71.2 ± 119.5 | 0.0 (-0.4; 0.3) | 0.0 (-0.5; 0.4)
| | | Social functioning | 79.4 ± 60.6 | 80.1 ± 56.5 | 0.0 (-0.4; 0.3) | 0.0 (-0.4; 0.4)
Lee, 2001 ^588^ | Periurethral injections of autologous fat (30cc of fat from the anterior abdominal wall or buttock through a single 2–3mm) with 3 maximum injections depending on outcomes measures | Placebo (saline) | Mean incontinence score | 10.9 ± 4.5 | 12.2 ± 4.6 | -0.3 (-0.8; 0.2) | -2.3 (-6.3; 1.6)
N = 68
Strasser, 2007 ^589^ | Transurethral ultrasonography -guided injections of autologous myoblasts and fibroblasts; regular training of the rhabdosphincter for 12 weeks and trans vaginal electrical stimulation for 4 weeks | Conventional endoscopic injections of collagen; regular training of the rhabdosphincte r for 12 weeks and trans vaginal electrical stimulation for 4 weeks | Quality-of-life score | 108.00±0.67 | 64.00±17.33 | 4.43 (3.48; 5.37) | 6.92 (5.4; 8.39)
N = 63 | | | Maximum residual urine (ml) | 13.83±43.65 | 8.81±24.49 | 0.13 (-0.39; 0.65) | 1.48 (-4.47; 7.43)
| | | Maximum urinary flow (ml/s) | 25.29±8.17 | 19.63±10.22 | 0.64 (0.10; 1.17) | 3.24 (0.51; 5.97)
| | | Maximum detrusor pressure during flow (cm/H2O) | 31.26±16.78 | 34.76±12.21 | -0.23 (-0.75; 0.30) | -0.65 (-2.16; 0.86)
| | | Maximum bladder capacity (ml) | 469.86±158.95 | 404.05±104.94 | 0.46 (-0.07; 0.99) | 0.11 (-0.02; 0.24)
| | | Maximum closure pressure at rest (cm H2O) | 40.52±15.81 | 35.24±10.94 | 0.37 (-0.16; 0.89) | 1.04 (-0.46; 2.54)
| | | Maximum closure pressure during voluntary contraction of rhabdosphincter (cm H2O) | 53.26±23.06 | 40.57±12.72 | 0.63 (0.09; 1.16) | 1.54 (0.22; 2.86)
| | | Periurethral EMG recording at rest (μV) | 44.23±15.01 | 31.57±10.86 | 0.92 (0.37; 1.47) | 2.91 (1.17; 4.65)
| | | Periurethral EMG recording during voluntary contraction of rhabdosphincter (μV) | 56.47±15.36 | 41.62±9.98 | 1.07 (0.52; 1.63) | 2.58 (1.24; 3.92)

Bold- significant differences in outcomes at 95% confidence level

Table F119 Effects of obstetric interventions on incidence and progression of urinary incontinence in females

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Dannecke, 2005 ^590^ | 146 primiparous women with an uncomplicated singleton pregnancy >34 weeks of gestation intending a vaginal delivery. | 1 Restrictive episiotomy - avoidance of episiotomy (for fetal indications only); 2 Liberal - in addition to fetal indications use episiotomy when a tear is judged to be imminent | Self reported presence of urinary and fecal incontinence with standardized questionnaire. | Intention-to-treat.
Followup RCT to examine the effects of restrictive use of mediolateral episiotomy vs. routine episiotomy. | Exclusion criteria: Previous surgery at the pelvic floor and neurological disorder. | | Anorectal manometry and urodynamic outcomes. Pelvic floor muscle strength with vaginal palpation. | Open label. Simple random sampling.
Duration: 18 months | Loss of followup: 45% in restrictive policy group, 32% in liberal policy group. | | Effort to contract the elevator; graded with the Oxford Score (4-strongest). | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Sartore, 2004 ^591^ | 519 consecutive primiparous women with singleton pregnancies and spontaneous vaginal delivery with fetal head in occiput anterior position, residents of Trieste. | 1 Mediolateral episiotomy; 2 No episiotomy | Stress urinary incontinence - observation of involuntary loss of urine synchronous with coughing (+stress test) with comfortably full bladder. Self reported urge incontinence - loss of urine associated with strong desire to void. | No intention to treat. Open label.
Non randomized CT to examine the effect of mediolateral episiotomy on puerperal pelvic floor strength and dysfunction. | Exclusion criteria: Not delivered in lithotomy position, cesarean delivery, third and fourth-degree perineal lacerations, preterm, breech, and operative delivery, anal and urinary incontinence that pre-existed vaginal delivery, and history of vaginal or anal surgery. | | Self reported anal incontinence - loss of flatus, liquid, or solid stool. Pelvic floor muscle strength scored 0–5. Vaginal manometry abnormal perineometric values <12cm H20. Urine stream interruption test abnormal any urine stream interruption test scores >5 seconds. | Groups were comparable at baseline except neonatal weight.
Duration: 3 months after vaginal delivery | | | | Crude odds ratios reported.
Hannah, 2002 ^592^ | 1,159 women with singleton live fetus in a frank or complete breech presentation at term (37 weeks' gestation). | 1 Planned vaginal birth group, management was expectant until spontaneous labor began, unless an indication to induce labor (e.g., post term pregnancy); 2 Planned cesarean delivery (egg, footling breech presentation) scheduled for 38 or more weeks' gestation. If the woman was in labor at the time of randomization, the caesarean section was undertaken as soon as possible. Immediately before caesarean section, the fetal presentation was reassessed and if cephalic, a vaginal birth was planned. | Self reported stress urinary incontinence and fecal or flatus incontinence within the previous 7 days. | Intention to treat.
Term Breech Trial, RCT to examine the effects of planned cesarean section on incontinence 3 months postpartum. | Exclusion criteria: Fetopelvic disproportion, fetus weight >4000g, hyperextension of the fetal head, lethal anomaly or a condition that might cause a mechanical problem at delivery, and contraindication to labor or vaginal delivery. | | Perception of incontinence: no problem at all, a little problem, or a big problem. | Open label.
Duration: 3 months | Loss of followup: 16.5% | | | Centralized randomization stratified by parity with block sizes of two. Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Hannah, 2004 ^593^ | 917 of 1,159 women with singleton live fetus in a frank or complete breech presentation at term (37 weeks' gestation). | 1 Planned vaginal birth group, management was expectant until spontaneous labor began, unless an indication to induce labor (e.g., post term pregnancy); 2 Planned cesarean delivery (egg, footling breech presentation) scheduled for 38 or more weeks' gestation. If the woman was in labor at the time of randomization, the caesarean section was undertaken as soon as possible. Immediately before caesarean section, the fetal presentation was reassessed and if cephalic, a vaginal birth was planned. | Self-reported stress urinary incontinence and fecal or flatus incontinence within the previous 3 to 6 months. Perception of incontinence: no problem at all, a little problem, or a big problem. | Intention to treat.
Followup to Term Breech Trial, RCT to examine the effects of planned cesarean section on incontinence 2 years postpartum. | Exclusion criteria: Fetopelvic disproportion, fetus weight >4000g, hyperextension of the fetal head, lethal anomaly or a condition that might cause a mechanical problem at delivery, and contraindication to labor or vaginal delivery. | | | Open label.
Duration: 2 years | Loss of followup: 20.9% in planned Cesarean groups and 19.6% in vaginal birth group. | | | Centralized randomization stratified by parity with block sizes of two. Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Klein, 2005 ^594^ | 1,044 women participated in RCT. | 1 Caesarean section; 2 Vaginal delivery | Self reported non specified and stress urinary incontinence 3 months postpartum. Severe incontinence-wearing a pad. | No intention to treat.
Multi center RCT to examine the urinary and sexual consequences of vaginal delivery compared with Caesarean section. | Exclusion criteria: not reported. | | | The article presented cohort analysis; subjects were grouped by received treatment, not by randomization status. Open label.
Duration: 3 months postpartum | Loss of followup: 4.3%, from 135 women delivered by Caesarean section, only 25 were randomized to this group. Cross treatment occurred due to the decision made by attending physician. | | | Randomization not reported. No justification for sample size.
Sleep, 1987 ^595^ | 1,000 women with live singleton fetus of at least 37 completed weeks' gestational age presenting cephalically and spontaneous normal vaginal delivery. | Two management policies aimed to minimize perineal trauma during spontaneous vaginal delivery: | Self reported presence of total, stress, and urge urinary incontinence. | No intention to treat.
Followup RCT to examine policies of restricted versus liberal episiotomy during spontaneous vaginal delivery on urinary incontinence. | Exclusion criteria: 15 participants from the original trial (8-not fluent in English; 2 refused to complete 3 month questionnaire; 3 had given the baby up for adoption; 1 baby had been taken into care; and 1 baby had died in the neonatal period). | 1 “Try to avoid episiotomy”: restrict episiotomy to fetal indications (fetal bradycardia, tachycardia, or meconium stained liquor); 2 “Try to prevent a tear” - use episiotomy more liberally to prevent tears. | Frequency of incontinency episodes. | Randomization procedure is not described.
Duration: 3 years postpartum. | Loss of followup: 33% of contacted participants did not respond to the survey 3 years postpartum. | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified for the original RCT.
Johanson, 1999 ^596^ | 607 women requiring assisted vaginal delivery. | 1 Delivery with vacuum extractor; 2 Forceps delivery. | Self reported fecal and urinary incontinence 5 years postpartum | No intention to treat.
Followup RCT to examine effects of delivery by forceps or vacuum extractor on maternal and child outcomes. | Exclusion criteria: 47% of participants from the original RCT were not contacted for unclear reasons. | | | Open label.
Duration: 5 years postpartum. | Loss of followup: 26.2% non responders to the survey 5 years postpartum. | | | Randomization procedure is not described. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Garcia, 2005 ^597^ | 51 women with complete third- or fourth-degree anal sphincter laceration who underwent primary repair at the time of vaginal delivery. | 1 End-to-end technique to repair obstetric anal sphincter lacerations: 4 separate sutures of polyglycolic acid to reapproximate the sphincter ends directly.; 2 Overlapping repair of obstetric anal sphincter lacerations used 3 sutures of 2–0 PDS to reapproximate the sphincter ends in an overlapping fashion. | Self reported urinary and anal incontinence graded with the Fecal Incontinence Score (FIS) from 18 - total incontinence >2/week, scores 1–3 incontinence of flatus only. Anal incontinence was defined as a fecal incontinence score of >0. | No Intention to treat.
RCT to examine effects of surgical techniques for the primary repair of obstetric anal sphincter lacerations. | Exclusion criteria: not reported | | | Single blind.
Duration: 4 months postpartum | Loss of followup: 35.6% | | | Computer-generated randomization table.
| | | | Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.

Table F120 Effects of obstetric interventions on incidence and progression of urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Improvement in urinary incontinence
Hannah, 2004 ^593^ | Planned cesarean delivery | Planned vaginal birth | Stress urinary incontinence no problem at all 2 years postpartum | 31 | 37 | 38.3 | 37.0 | 0.8 (0.5; 1.3)
N = 2,088
Sleep, 1987 ^595^ | Restrictive policy for episiotomy | Liberal policy for episiotomy | Self reported urinary incontinence 3 months postpartum, no pads | 38 | 45 | 7.6 | 9.0 | 0.9 (0.6; 1.3)
N = 1,000
Risk of urinary incontinence
Dannecke, 2005 ^590^ | Restrictive episiotomy | liberal episiotomy | Self reported urinary incontinence 18 months postpartum | 13 | 11 | 48.0 | 27.0 | 1.3 (0.6; 2.7)
N = 146
Sartore, 2004 ^591^ | Mediolateral episiotomy | No episiotomy | % with stress urinary incontinence (+ stress test) | 33 | 32 | 12.9 | 12.1 | 1.1 (0.7; 1.7)
N = 519 | | | % with self reported urge urinary incontinence | 5 | 2 | 1.9 | 0.7 | 2.6 (0.5; 13.3)
Hannah, 2004 ^593^ | Planned cesarean delivery | Planned vaginal birth | Self reported stress urinary incontinence 2 years postpartum | 81 | 100 | 17.8 | 21.8 | 0.8 (0.6; 1.1)
N = 2,088 | | | Self reported stress urinary incontinence 3 months postpartum | 36 | 58 | 4.5 | 7.3 | 0.6 (0.4; 0.9) | 36 (23; 208) | 28 (5; 43)A
| | | Stress urinary incontinence 3 months postpartum is not a problem at all | 4 | 17 | 16.7 | 37.0 | 0.2 (0.1; 0.7) | 5 (3; 9) | 203 (112; 341)A
Sleep, 1987 ^595^ | Restrictive policy for episiotomy | Liberal policy for episiotomy | Self reported total incontinence of urine <1/week | 69 | 82 | 13.9 | 16.3 | 0.8 (0.6; 1.1)
N = 1,000 | | | Self reported total incontinence of urine 1–2 times/week | 37 | 35 | 7.4 | 7.0 | 1.1 (0.7; 1.7)
| | | Self reported total incontinence of urine >3 times/week | 6 | 7 | 1.2 | 1.4 | 0.9 (0.3; 2.6)
| | | Self reported stress urinary incontinence | 103 | 105 | 20.7 | 20.9 | 1.0 (0.8; 1.3)
| | | Self reported urge urinary incontinence | 41 | 41 | 8.2 | 8.2 | 1.0 (0.7; 1.5)
Johanson, 1999 ^596^ | Delivery with vacuum extractor | Forceps delivery | Self reported stress urinary incontinence sometimes | 46 | 41 | 15.5 | 13.2 | 1.2 (0.8; 1.7)
N = 607 | | | Self reported urge urinary incontinence sometimes | 30 | 32 | 10.1 | 10.3 | 1.0 (0.6; 1.6)
Garcia, 2005 ^597^ | End-to-end repair technique | Overlapping repair technique | Self reported urinary incontinence 4 months postpartum | 1 | 4 | 4.3 | 22.2 | 0.2 (0.0; 1.6)
N = 41
Hannah, 2002 ^592^ | Planned cesarean delivery | Planned vaginal birth | Stress urinary incontinence 3 months postpartum is big problem | 5 | 6 | 20.8 | 13.0 | 0.8 (0.3; 2.7)
N = 2,088
Klein, 2005 ^594^ | Caesarean section | Vaginal delivery | Self reported urinary incontinence in primiparous | | | | | 0.3 (0.1; 0.7)
N = 1,044 | | | Self reported urinary incontinence in multiparous | | | | | 0.9 (0.3; 2.8)
| | | Self reported urinary incontinence in primiparous without history of UI | | | | | 0.2 (0.1; 1.0)
| | | Self reported urinary incontinence in primiparous with history of UI | | | | | 0.3 (0.1; 0.9)
| | | Self reported urinary incontinence in multiparous without history of UI | | | | | 0.7 (0.2; 14.8)
| | | Self reported urinary incontinence in multiparous with history of UI | | | | | 0.8 (0.2; 2.8)
| | | Self reported stress urinary incontinence in primiparous | | | | | 0.3 (0.2; 0.5)
| | | Self reported stress urinary incontinence in multiparous | | | | | 0.6 (0.3; 1.5)
| | | Self reported stress urinary incontinence in primiparous without history of UI | | | | | 0.3 (0.0; 0.6)
| | | Self reported stress urinary incontinence in primiparous with history of UI | | | | | 0.3 (0.1; 0.6)
| | | Self reported stress urinary incontinence in multiparous without history of UI | | | | | 0.8 (0.2; 3.8)
| | | Self reported stress urinary incontinence in multiparous with history of UI | | | | | 0.6 (0.2; 1.7)
| | | Self reported severe (wearing pads) incontinence in primiparous | | | | | 1.0 (0.2; 4.6)
| | | Self reported severe (wearing pads) incontinence in multiparous | | | | | 1.1 (0.2; 5.5)
Severity of urinary incontinence
Hannah, 2004 ^593^ | Planned cesarean delivery | Planned vaginal birth | Stress urinary incontinence is a big problem 2 years postpartum | 3 | 9 | 3.7 | 9.0 | 0.3 (0.1; 1.2)
N = 2,088
Sleep, 1987 ^595^ | Restrictive policy for episiotomy | Liberal policy for episiotomy | Self reported urinary incontinence severe to wear pads, sometimes | 26 | 24 | 5.2 | 4.8 | 1.1 (0.6; 1.9)
N = 1,000 | | | Self reported urinary incontinence severe to wear pads, every day | 5 | 4 | 1.0 | 0.8 | 1.3 (0.3; 4.7)
| | | Self reported urinary incontinence 3 months postpartum, pads | 19 | 15 | 3.8 | 3.0 | 1.3 (0.7; 2.5)
Johanson, 1999 ^596^ | Delivery with vacuum extractor | Forceps delivery | Self reported frequent stress urinary incontinence | 8 | 12 | 2.7 | 3.9 | 0.7 (0.3; 1.7)
N = 607 | | | Self reported frequent urge urinary incontinence | 4 | | 1.4 | 0.0

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F121 Effects of obstetric interventions on progression of urinary incontinence in females (instrumental severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Dannecke, 2005 ^590^ | Restrictive episiotomy | liberal episiotomy | Pelvic floor contraction strength (oxford score 0–4) | 2.2 ± 1.3 | 2.6 ± 1.3 | -0.3 (-0.6; 0.0) | -11.8 (-24.4; 0.7)
N = 146 | | | Functional urethral length (rest), mm | 34.0 ± 8.2 | 30.0 ± 6.4 | 0.5 (0.2; 0.9) | 1.8 (0.7; 2.9)
| | | Functional urethral length (contraction) mm | 29.0 ± 15.0 | 25.0 ± 8.0 | 0.3 (0.0; 0.7) | 1.3 (0.0; 2.7)
| | | Maximum urethral closure pressure (rest), mmH2O | 98.0 ± 24.0 | 101.0 ± 28.0 | -0.1 (-0.4; 0.2) | -0.1 (-0.4; 0.2)
| | | Maximum urethral closure pressure (contraction) cmH2O | 95.0 ± 30.0 | 103.0 ± 38.0 | -0.2 (-0.6; 0.1) | -0.2 (-0.5; 0.1)
Sartore, 2004 ^591^ | Mediolateral episiotomy | No episiotomy | Urine stream interruption test score(s), % abnormal | 3.9 ± 3.5 | 3.8 ± 2.9 | 0.0 (-0.1; 0.2) | 0.8 (-3.7; 5.4)
N = 519

Bold- significant differences in outcomes at 95% confidence level

Table F122 Effects of hysterectomy on incidence and progression of urinary incontinence in females

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Gimbel, 2003 ^598^ | 319 women going to have a hysterectomy for benign diseases of the uterus able to read and write Danish. | 1 Total abdominal hysterectomy; 2 Subtotal abdominal hysterectomy | Self reported urinary incontinence defined as ‘always’ or ‘often’ using the validated, self administered, postal questionnaire | Intention to treat.
RCT to examine effects of total abdominal hysterectomy and subtotal abdominal hysterectomy performed for benign uterine diseases. | Exclusion criteria: Laparoscopic or vaginal hysterectomy, dysplasia of cervix, prolapse of uterus, former operation for a urological diseases, former or present malignancy, diabetes, neurological diseases, alcoholism, poor mental function. | | | Open label, statistician was blinded. Restricted, computer-generated block randomization (1:1) stratified by clinical centers and clinical groups. Within each stratum, random permuted block sizes of 2, 4 and 6 occurred.
Duration: 1 year | Loss of followup: 13.2% excluded from the intention to treat analysis | | | Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Thakar, 2002 ^599^ | 279 women referred for hysterectomy because of benign disease; most of the women were premenopausal. | 1 Subtotal hysterectomy; 2 Total hysterectomy | Self reported urinary incontinence using standardized Questionnaire. | No intention to treat for cystometry outcomes. Double blind.
RCT to examine effects of total abdominal hysterectomy and subtotal abdominal hysterectomy performed for benign uterine diseases. | Exclusion criteria: Age >60 years, suspected cancer, body weight that exceeded 100kg, previous pelvic surgery, known endometriosis, abnormal cervical smears, symptomatic uterine prolapse, and symptomatic urinary incontinence for which the patient might seek expert medical advice. | | Stress incontinence scores from 0-none to 4-always. Twin-channel subtracted cystometrography and uroflowmetry outcomes. | Randomization with computer-generated numbers. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
Duration: 1 year | Loss of followup: 16% in total and 12% in subtotal abdominal hysterectomy groups. | | | Sample size justified.
Lalos, 1986, ^600^ | 22 women admitted to the hospital for hysterectomy. | 1 Subtotal hysterectomy; 2 Total hysterectomy | Urodynamic outcomes | Intention to treat not stated. Open label.
RCT to examine effects of subtotal or total hysterectomy on urinary symptoms. | Exclusion criteria: pathological findings of the cervix. | | | Randomization and allocation concealment not reported. Baseline data not analyzed for comparability.
Duration of followup: 6 weeks. | Loss of followup: not reported | | | Sample size not justified.
Kaya, 2004 ^601^ | 90 women undergoing total abdominal hysterectomy. | 1 Extrafascial total abdominal hysterectomy; 2 Intrafascial total abdominal hysterectomy | Surgical morbidity and presence of urge incontinence defined as urodynamically established detrusor overactivity at the end of 12 months | No intention to treat.
RCT to examine effects of extrafascial and intrafascial total abdominal hysterectomy on urinary urge incontinence. | Exclusion criteria: gynecologic malignancy, stress incontinence, inflammatory bladder disorders, other gynecological surgery. | | | Open label.
Duration of followup: 12 months | Loss of followup: 11.1% | | | Randomization with random numbers tables. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Learman, 2003 ^602^ | 135 premenopausal women over 30 years who had abdominal hysterectomy for symptomatic uterine leiomyomata, abnormal uterine bleeding refractory to hormonal treatment, or both, follicle stimulating hormone <30mIU/ml, and endometrial biopsy within 6 months was negative for hyperplasia or carcinoma. | 1 Total abdominal hysterectomy (removal of both the corpus uteri and cervix uteri); 2 Subtotal supracervical hysterectomy | Self reported urinary incontinence using questionnaires with checklists and Likert scales | Intention to treat.
RCT to examine effects of total versus supracervical abdominal hysterectomy on clinical outcomes during 2 years of followup. | Exclusion criteria: Age >50 years at screening, positive results of pregnancy test, desire for future childbearing, known or suspected genital tract carcinoma, cervical dysplasia or carcinoma-in-situ, complex or atypical endometrial hyperplasia, candidate for vaginal hysterectomy (as determined by their gynecologist), and unlikely to remain geographically accessible for 4 years. | | | Open label.
Duration: 2 years. | Loss of followup: 4% assigned to total and 10% assigned to supracervical abdominal hysterectomy. | | | Stratified by clinical center computer-generated
| | | | Randomization with permuted blocks 4, 6, and 8. Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Long, 2005 ^603^ | 94 women with various indications for hysterectomy but no indication of uterine myomas. | 1 Laparoscopic hysterectomy without vaginal cuff suspension. Patients with severe SUI underwent concomitant anti-incontinence procedures; 2 Laparoscopic hysterectomy with vaginal cuff suspension: the use of absorbable polyglactin sutures through the cardinaluterosacral ligament complex, anchoring bilaterally to 3cm near the angle of vaginal cuff. Patients with severe SUI underwent concomitant anti-incontinence procedures | Q-tip test, introital ultrasonography, and personal interviews using the Bristol Female Lower Urinary Tract Symptoms Questionnaire. | No Intention to treat. Open label.
RCT to examine the effects of vesicourethral function following laparoscopic hysterectomy with and without vaginal cuff suspension on urinary incontinence. | Exclusion criteria: incomplete records, combined procedures (colposuspension or tension-free vaginal tape procedure). | | Stress urinary incontinence - urine leakage during stress urethral pressure profilometry. Intrinsic sphincter deficiency - maximum urethral closure pressure <20cm/H2O at maximum cystometric capacity. | Computer-generated numbers. Allocation concealment unclear.
Duration of follow up: 6 months | Loss of follow up: 10.5% | | Sever stress incontinence - urine leakage during the pad test >10g. The anatomic position and dynamic mobility of the bladder neck by introital ultrasonography and Q-tip test with patients in the semi-supine position. | Baseline data confirmed adequacy of randomization.
| | | | Sample size justified

Table F123 Effects of hysterectomy on incidence and progression of urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI)
Sample
Kaya, 2004 ^601^ | Extrafascial total abdominal hysterectomy | Intrafascial total abdominal hysterectomy | Recover from urge urinary incontinence (cured) | 4 | 14 | 8.89 | 31.11 | 0.29 (0.10; 0.80) | 5 (4; 16)
N = 90 | | | Develop urge urinary incontinence (incidence) | 0 | 4 | 0.10 | 9.50 | 0.11 (0.01; 2.01)
| | | Postoperative urge urinary incontinence | 10 | 8 | 22.22 | 17.78 | 1.25 (0.54; 2.87)
Learman, 2003 ^602^ | Subtotal supracervical hysterectomy | Total abdominal hysterectomy | Self reported stress incontinence 1 year postpartum | 8 | 6 | 13.00 | 9.50 | 0.66 (0.24; 1.83)
N = 135 | | | Self reported stress incontinence 2 years postpartum | 8 | 3 | 13.00 | 4.70 | 2.63 (0.73; 9.48)
| | | Self reported urge urinary incontinence 1 year postpartum | 5 | 5 | 8.20 | 7.90 | 0.99 (0.30; 3.25)
| | | Self reported urge urinary incontinence 2 years postpartum | 4 | 2 | 6.60 | 3.10 | 1.97 (0.37; 10.40)
Gimbel, 2003 ^598^ | Subtotal abdominal hysterectomy | Total abdominal hysterectomy | Self reported urinary incontinence, always or often 1 year post operation | 24 | 18 | 21.00 | 9.00 | 1.31 (0.74; 2.31)
N = 319 | | | Proportion of urinary incontinence symptom relief 1 year post operation | 14 | 20 | 8.70 | 12.66 | 0.69 (0.36; 1.31)
| | | Proportion of women with new symptoms of urinary incontinence 1 year post operation | 10 | 3 | 6.21 | 1.90 | 3.27 (0.92; 11.66)
Thakar, 2002 ^599^ | Subtotal hysterectomy | Total hysterectomy | Self-reported urge urinary incontinence at 12 months post operation | 13 | 14 | 9.77 | 9.59 | 1.02 (0.50; 2.09)
N = 279
Long ^603^ | Laparoscopic hysterectomy without vaginal cuff suspension | Laparoscopic hysterectomy with vaginal cuff suspension | Stress incontinence | 6 | 6 | 15.79 | 15.79 | 1.00 (0.35; 2.82
N = 76 | | | Severe | 3 | 2 | 7.89 | 5.26 | 1.50 (0.27; 8.48)
6 months | | | Mild to moderate | 3 | 4 | 7.89 | 10.53 | 0.75 (0.18; 3.13)
| | | BN hypermobility | 17 | 8 | 44.74 | 21.05 | 2.13 (1.04; 4.32) | 4 (1; 1601)

Bold- significant differences in outcomes at 95% confidence level

Table F124 Effects of hysterectomy on self reported and objectively measured severity of urinary incontinence

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Thakar, 2002 ^599^ | Subtotal hysterectomy | Total hysterectomy | Scores of stress urinary incontinence at 12 months post operation (4-always) | 1.5 ± 0.9 | 1.5 ± 0.9 | 0.0 (-0.2; 0.2) | 0.0 (-15.7; 15.7)
N = 279 | | | Scores of urinary urgency at 12 months post operation (4-always) | 2.0 ± 1.4 | 2.0 ± 1.3 | 0.0 (-0.2; 0.2) | 0.0 (-11.7; 11.7)
| | | Peak flow rate (ml/sec) | 21.2 ± 14.1 | 21.6 ± 19.9 | 0.0 (-0.3; 0.2) | -0.1 (-1.2; 1.0)
| | | First desire to void, ml | 229.7 ± 114.3 | 237.3 ± 106.6 | -0.1 (-0.3; 0.2) | 0.0 (-0.1; 0.1)
| | | Strong desire to void, ml | 303.4 ± 141.9 | 318.1 ± 129.3 | -0.1 (-0.3; 0.1) | 0.0 (-0.1; 0.0)
| | | Maximum capacity, ml | 391.5 ± 124.7 | 394.0 ± 130.4 | 0.0 (-0.3; 0.2) | 0.0 (-0.1; 0.1)
Lalos, 1986 ^600^ | Subtotal hysterectomy | Total hysterectomy | Nightly micturition/week | 2.6 ± 3.1 | 1.5 ± 2.2 | 0.4 (-0.4; 1.3) | 27.3 (-29.1; 83.6)
N = 22 | | | Bladder volume, ml | 494.0 ± 132.0 | 541.0 ± 125.0 | -0.4 (-1.2; 0.5) | -0.1 (-0.2; 0.1)
| | | Bladder compliance, ml/mmHg | 70.4 ± 25.2 | 98.1 ± 34.0 | -0.9 (-1.8; 0.0) | -0.9 (-1.8; 0.0)
| | | Intravesical pressure at maximum urine flow, mmHg | 33.0 ± 6.0 | 38.0 ± 7.0 | -0.8 (-1.6; 0.1) | -2.0 (-4.3; 0.3)
| | | Maximum flow rate, ml/s | 21.9 ± 6.5 | 19.6 ± 5.7 | 0.4 (-0.5; 1.2) | 1.9 (-2.4; 6.2)
| | | Urethral conductance (ml2*sec2*mmHg-1) | 16.8 ± 12.7 | 11.7 ± 8.0 | 0.5 (-0.4; 1.3) | 4.1 (-3.1; 11.4)
Long, 2005 ^603^ | Laparoscopic hysterectomy without vaginal cuff suspension | Laparoscopic hysterectomy with vaginal cuff suspension | Q-tip straining angle (degrees) | 38.70 ± 10.00 | 33.80 ± 9.20 | 0.51 (0.05; .97) | 1.51 (0.16; 2.86)
N = 76

Bold- significant differences in outcomes at 95% confidence level

Table F125 Effects of vaginal tapes and sling procedures on risk and progression of incontinence in females

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Schraffordt Koops, 2006 ^604^ | 809 women with indication for TVT who had a history of previous incontinence or prolapse surgery were recruited from the Netherlands TVT database, 28 teaching and 13 local hospitals, patients of 54 gynecologists and urologists who performed tension-free vaginal tape. | Tension-free vaginal tape (Gynecare, Ethicon Inc, Sommerville, NJ) was performed with Ulmsten's method. | Stress urinary incontinence as a positive response to the question “Do you experience urinary leakage during physical activity, coughing or sneezing?” | Clinic based not random sampling.
Prospective cohort study to examine effects of tension-free vaginal tape in women with a history of surgery for urinary incontinence and/or prolapse. | Exclusion criteria: Recurrent and difficult to-treat urinary tract infections, predominant symptoms of urge urinary incontinence (defined as urge incontinence being more prevailing than the stress incontinence), detrusor overactivity at cystometry, post voiding bladder retention (>150ml), bladder capacity <200ml, or a physical/mental impairment that would make participation impossible. | | Incontinence Impact Questionnaire (IIQ-7) and Urogenital Distress Inventory (UDI-6) ranked with 4-step scale from “not at all” to “greatly” impaired. | Adjustment was not reported. Sample size not justified.
Duration: 2–36 months. | Loss of followup: 1.8% | | The total score was transformed to a scale from 0 as continent to 100
Rafii, 2004 ^605^ | 186 females with urodynamically confirmed stress urinary incontinence undergoing TVT. | 1 Tension-free vaginal tape with Ulmsten's method alone; 2 Tension-free vaginal tape with Ulmsten's method and concomitant vaginal hysterectomy.; 3 Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction. | Postoperative voiding diaries, standing stress-test results, and patient satisfaction. | Clinic based not random sample.
Case-control study to examine effects of tension-free vaginal tape alone or in conjunction with vaginal procedures on stress or mixed urinary incontinence in women. | Exclusion criteria: not reported. | | Objectively cured - no stress incontinence (clinical stress provocation test and urodynamic examinations) and no urinary retention (residual urine volume >150ml or more). Subjective Cured - improvement and failure rates based on the Contilife 28-item questionnaire. | Adjustment was not reported. Sample size not justified.
Duration of followup: 24 months | Loss of followup: none
Rechberger, 2003 ^606^ | 100 patients with stress urinary incontinence confirmed by a urodynamic profile including cystometry and urethral pressure profile. | 1 Monofilament tape inserted at the midurethra using the tension-free vaginal tape delivery instrument; 2 Multifilament tape using the intravaginal slingplasty delivery instrument | Urinary continence - no stress urinary incontinence symptoms; negative cough tests in the supine and standing positions; no need of hygienic pads. “improvement”-negative cough test but patients still experienced stress urinary leakage (much less frequent than previously) and the pads were occasionally wet. | Intention to treat not stated. Single blind. Simple computer generated randomization.
RCT to examine effects of monofilament and multifilament tapes positioned without tension at the midurethra on urinary incontinence. | Exclusion criteria: Intrinsic sphincter deficiency, other gynecologic disease, such as uterine myoma, ovarian cyst or severe uterine or vaginal prolapse. | | | Allocation concealment not reported. Baseline data not reported.
Duration of followup: 13.5 months | Loss of followup: not reported. | | | Sample size not justified.
Wadie, 2005 ^607^ | 53 female patients older than 21 years with stress urinary incontinence as leading symptom, life expectancy >1 year, normal upper tract, and normal manual dexterity. | 1 Fascial sling with free ends of flap fixed by a 1-zero polyglactin suture and the sling is fixed to the underlying periurethral fascia using 4-zero polyglactin sutures at the 6 and 12 o'clock positions; 2 Tension-free vaginal polypropylene tape | Urinary continence (cure) as complete dryness with no usage of pads, anti-incontinence surgery response score of 0 and negative stress test, Failure - visible leakage on stress test and a total score of 6. | Intention to treat not stated. Open label.
RCT to examine effects of fascial sling or polypropylene tape stress urinary incontinence. | Exclusion criteria: Bladder or urethral pathology, as well as those with cystocele greater than grade 2, pelvic or vaginal surgery within 6 months, predominant urge incontinence, active urinary tract infection as evidenced by positive urine culture. | | | Randomization with simple random numbers table.
Duration of followup: 6 months | Loss of followup: not reported. | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Lightner, 2001 ^586^ | 355 women diagnosed with stress urinary incontinence due to intrinsic sphincter deficiency, abdominal leak point pressure of less than 90cm/H2O, who failed prior surgical and medical treatment. | Injection of bulking agent 1.0ml Durasphere maximum 5 times with a minimum 7 day interval. | Self reported urinary incontinence with grade 0 (dry) to grade 3 (continuous urinary leakage) | No Intention to treat. Double-blind.
RCT to examine effects of bulking agents on stress urinary incontinence due to intrinsic sphincter deficiency in women. | Exclusion criteria: Prior injections of any urethral bulking agents, positive intradermal test injections of bovine collagen and beta-glucan. | Injection of bulking agent bovine collagen maximum 5 times with a minimum 7 day interval. | | Randomization and allocation concealment not reported. Baseline data not reported.
Duration of followup: 12 months | Loss of followup: 38% | | | Sample size not justified.
Adamiak, 2002 ^608^ | 103 women with objectively confirmed stress urinary incontinence. | 1 Tension-free vaginal tape with local analgesia (injection of 0.5–0.75% lidocaine hydrochloride in subcutaneous tissue).; 2 Tension-free vaginal tape with spinal analgesia (0.5% bupivacaine hydrochloride administered at L_3_–L_4_ or L_4_–L_5_ interspace) | Self reported urinary incontinence symptoms with three grades using Ingelman-Sundberg scale | No Intention to treat. Open label.
RCT to examine effects of tension-free vaginal tape using local or spinal anesthesia on female stress urinary incontinence | Exclusion criteria: mixed urinary incontinence | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 6 months | Loss of followup: 2.9% | | | Sample size not justified.
Ward, 2002 ^609^ | 344 women with urodynamic stress incontinence. | 1 Tension-free vaginal tape procedure performed as described by Ulmsten, under local anesthesia and sedation.; 2 Colposuspension was performed according to standard technique. | Self reported urinary incontinence using SF-36, the Bristol female lower urinary tract symptoms questionnaire, the EQ-5D health questionnaire. One week urinary diary, one hour perineal pad test, and cystometry outcome. objective cure of stress incontinence based on a negative stress test on urodynamic testing, combined with a negative one hour pad test (<1g change in weight). | Intention to treat.
RCT to examine effects of tension-free vaginal tape or colposuspension on female stress incontinence. | Exclusion criteria: Detrusor overactivity, vaginal prolapse requiring treatment, previous surgery for prolapse or incontinence, a major degree of voiding dysfunction (voiding pressure >50cm H20, maximum flow <15ml/s, and residual urine volume >100ml), neurological disease, and allergy to local anesthetic. | | | Open label.
Duration of followup: 6 months | Loss of followup: 3.5% | | | Computer generated randomization with permuted blocks of four and six.
| | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Valpas, 2004 ^610^ | 128 women with urodynamic stress incontinence, unequivocal indication for operation according to the clinic's standards, urodynamically confirmed stress incontinence (stabile bladder in cystometry), positive stress test result (300ml of saline in the bladder, maximum repetitive coughs in a supine position. | 1 Tension-free vaginal tape under local anesthesia with polypropylene mesh tape placed under the midurethra.; 2 Laparoscopic mesh colposuspension under general anesthesia (Hannah and Chin) | Urinary continence as negative stress test and negative 48-hour pad test (weight gain of pads was less than 8g in 48 hours). Urinary Incontinence Severity Score 0, 1, or 2 (no, slight, or marked impairment of quality of life, respectively) 0 - no inconvenience at all, 20 - maximal inconvenience. Urge Score: >7 indicates increased risk of motor urge incontinence. King's College Health Questionnaire with 21 questions in 8 domains, with separate scales, to measure the severity of urinary symptoms. | No Intention to treat. Open label.
Double publication: Valpas 2003 ^611^ | Exclusion criteria: Age older than 70 years, previous incontinence surgery, more than 3 episodes of urinary tract infection within the last 2 years, coincident other gynecological surgery, body mass index more than 32 kg/m(2), urethral closure pressure less than 20cm/H2O, and residual volume more than 100ml in preoperative urodynamic evaluation | | Scores in the domains range from 0 to 100, a higher score indicating greater quality of life impairment. | Computer-generated randomization separately for each center. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine effects of tension-free vaginal tape or laparoscopic mesh colposuspension on female stress urinary incontinence. | Loss of followup: 5.4% | | | Sample size justified.
Duration of followup: 12 months
deTayrac, 2004 ^612^ | 61 women with urodynamically proved genuine stress incontinence | 1 Tension-free vaginal tape.; 2 Transobturator suburethral tape | Self reported symptoms of urinary incontinence in visual analog scale ranging from 0 to 10 (0 - no symptoms to 10 - maximum severity) “objectively cured” - negative stress test, “objectively improved” - improvement of SUI but positive stress test | Intention to treat not stated. Computer-generated random allocations in a ratio of 1:1 in balanced blocks of 10.
RCT to examine effects of tension-free vaginal tape or transobturator suburethral tape on female stress urinary incontinence. | Exclusion criteria: Predominant urge incontinence, urodynamic detrusor instability, prolapse. | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
Duration of followup: 12 months | Loss of followup: not reported | | | Sample size justified
Andonian, 2005 ^613^ | 84 women with urodynamic stress incontinence with or without pelvic organ prolapse, stable bladder function and good flow rates without clinically significant post-void residual, who failed anti-incontinence surgeries or bulking agent treatments. | 1 Suprapubic arch sling; 2 Tension-free vaginal tape by Ulmsten. | Objective cure as 1-hour pad test of ≤2g Incontinence Impact Questionnaire score: <50 - good quality of life, 50–70 - moderate QoL, and >70 - poor quality of life | No intention to treat. Single blind.
RCT to examine effects of suprapubic arch sling or tension-free vaginal tape on female stress urinary incontinence. | Exclusion criteria: Mixed urinary incontinence with abnormal capacity, compliance and uninhibited contractions, obstructive, unstable bladder functions, or neurogenic bladders, and urinary tract infection. | Anterior and posterior colporrhaphy, and vaginal hysterectomy were performed simultaneously in symptomatic women with pelvic organ prolapse | | Randomization with random numbers table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
Duration of followup: 12 months | Loss of followup: 1.2% | | | Sample size justified.
Lim, 2005 ^614^ | 195 consenting patients with urodynamic stress incontinence that failed conservative management for symptomatic stress incontinence, or required prophylactic incontinence surgery during prolapse repair for occult stress incontinence (no subjective stress leakage but urodynamic incontinence). | 1 Suburethral slingplasty with tension-free vaginal tape macroporous monofilament threads, inserted using ‘bottom to top’ (caudocranial) approach.; 2 Suburethral slingplasty with intravaginal sling multifilament threads with much smaller pore sizes, inserted using ‘bottom to top’ (caudocranial) approach.; 3 Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads, with an absorbable tensioning suture that is designed to aid tape tension adjustment inserted with a ‘top to bottom’ (craniocaudal) approach. | Urodynamic stress incontinence as positive cough leak with 300ml of water either in supine or erect position. intrinsic sphincter deficiency as maximum urethral closure pressure <20cm water. | No Intention to treat. Single blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine effects of three types of suburethral slings on female urodynamic stress incontinence. | Exclusion criteria: Past history of urogenital malignancy, fistula or pelvic radiotherapy. | | Improvement in urinary incontinence as >50% reduction in frequency of occurrence compared to preoperative state. | Sample size justified
Duration of followup: 12 months | Loss of followup: 6.7%
Lord, 2006 ^615^ | 313 women with clinical diagnosis of stress urinary incontinence and a recommendation of minimally invasive sling surgery to treat their symptoms with possible previous incontinence and/or other pelvic surgery including combined treatment with other pelvic operations, e.g., vaginal hysterectomy and repair. | 1 Tension-free vaginal tape; 2 Suprapubic urethral support sling | Subjective cure from stress urinary incontinence as no use of protection, improvement in symptoms and a scale of improvement (1–100). The objective definition of cure as observed absence of urinary leakage in stress cough test while supine and with a comfortably full bladder. | Intention to treat.
RCT to examine effects of tension-free vaginal tape and suprapubic urethral support sling on female stress incontinence. | Exclusion criteria: Age <18 years, pregnancy, major voiding dysfunction specified as an abnormal flow (i.e. maximum urinary flow rate <10ml/s) or residual urinary volume of >150ml. | | | Double blind.
Duration of followup: 6 weeks | Loss of followup: 4.3% | | | Central computer generated random numbers stratified based on previous surgery and experience of surgeon with permuted blocks of four, six and eight. Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified
Meschia, 2006 ^616^ | 190 women with primary urodynamic stress incontinence and urethral hypermobility. | 1 Tension-free vaginal tape under local or epidural anesthesia.; 2 Intravaginal slingplasty under local or epidural anesthesia. | Objective cure as no leakage of urine in stress cough test, with at least 300ml of saline solution in the bladder and as a pad weight gain <1g during the 1-hour test. Subjective cure as no urine loss during “stress” and failure as any reported leakage of urine during exertion. | No Intention to treat. Open label.
RCT to examine effects of tension-free vaginal tape or intravaginal slingplasty on female stress urinary incontinence. | Exclusion criteria: Previous anti-incontinence surgery, vaginal prolapse requiring treatment, coexisting pelvic pathology, known bleeding diathesis or current anticoagulant therapy, detrusor overactivity, and urethral hypomobility (difference in Q-tip % 20 degrees from horizontal with straining). | | | Centralized computer-generated random list. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 2 years | Loss of followup: 15.37% | | | Sample size justified
Arunkalaivanan, 2003 ^617^ | 142 women with urodynamic genuine stress incontinence. Exclusion criteria: Detrusor instability. | 1 Porcine dermal sling (pelvicol implant) by Barrington; 2 Tension-free vaginal tape by Ulmsten | Cure as no leakage in stress cough test, patient self reported urinary continence “dry,” improvement in quality of life scores >90% | Intention to treat not stated. Open label.
RCT to examine effects of porcine dermal sling or tension-free vaginal tape on female stress incontinence. | Loss of followup: none. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 12 months | | | | Sample size not justified.
David-Montefiore, 2006 ^618^ | 88 women undergoing sub-urethral sling procedure for stress urinary incontinence. | 1 Retropubic suburethral sling procedure using I-STOP® device macroporous (>75-micron pore size) non-elastic monofilament polypropylene mesh; 2 Transobturator suburethral sling procedure using I-STOP® device macroporous (>75-micron pore size) non-elastic monofilament polypropylene mesh | Self reported urinary continence (dry) and improvement in symptoms. | No Intention to treat. Open label. Computer-generated randomization Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine effects of retropubic and transobturator suburethral sling procedure on female urinary stress incontinence. | Exclusion criteria: not reported | | | Sample size justified.
Duration of followup: 24 months | Loss of followup: none
Dietz, 2005 ^619^ | 195 women with urinary incontinence. | Two-dimensional (2D) and threedimensional (3D) pelvic floor ultrasound with a 7–4MHz volume transducer. | Self reported urinary continence (cured or improved). Free flowmetry outcomes. | No Intention to treat. Single blind.
RCT to examine effects of suburethral slings on female urinary incontinence. | Exclusion criteria: missing data | 1 Tensionless vaginal tape; 2 Intravaginal sling; 3 Suprapubic arc sling | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization Sample size justified.
Duration of followup: 23 months | Loss of followup: 6.7%
Maher, 2005 ^620^ | 45 women with stress urinary incontinence and intrinsic sphincter deficiency diagnosed by maximum urethral closure pressure <20cm/H2O who failed to respond to conservative treatments. | 1 Pubovaginal 11–12cm sling by McGuire positioned suburethrally at the proximal urethra; 2 Transurethral macroplastique | Self reported urinary incontinence using validated questionnaires [Short Urinary Distress Inventory (SUDI) and Incontinence Impact Questionnaire (IIQ). | Intention to treat.
RCT to examine effects of pubovaginal sling or transurethral macroplastique on female stress urinary incontinence and intrinsic sphincter deficiency. | Exclusion criteria: Required prolapse surgery, previous sling procedure, contraindications for general anesthesia. | | 1-hour pad test. | Open label.
Duration of followup: 1 year and 5 years | Loss of followup: 4.4% | | Objective success was defined as no urinary leakage due to stress urinary incontinence on repeat urodynamic studies | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization Sample size justified.
Abdel-Fattah, 2004 ^621^ | 142 women with pure stress urinary incontinence | 1 Pelvicol pubovaginal sling; 2 Tension-free vaginal tape | Self reported urinary continence (dry) and improvement in urinary incontinence symptoms. Pad use. | No intention to treat. Open label.
RCT to examine effects of Pelvicol pubovaginal sling or tension-free vaginal tape on females urodynamic stress incontinence | Exclusion criteria: not reported | | | Randomization using random numbers table.
Duration of followup: 3 years | Loss of followup: 4.2% | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Darai, 2007 ^622^ | 88 women older than 18 years undergoing suburethral sling procedure for urodynamic stress urinary incontinence (some had mixed incontinence). | 1 Suburethral sling procedure with retropubic routes by Ulmsten; 2 Suburethral sling procedure with transobturator routes by Delorme | Objective cure from stress urinary incontinence: no stress incontinence by clinical and urodynamic and during stress provocation test, and no urinary retention or a residual urine volume of <150ml. | Intention to treat not stated. Open label. Computer-generated randomization code. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine effects of suburethral sling procedure on female urinary stress incontinence | Exclusion criteria: Previous history of radio- or chemotherapy, use of anticoagulants or antipsychotic medications, and pregnancy. | | Objective improvement - no incontinence in stress provocation test. Self reported quality of life using Urinary Distress Impact Questionnaire [UDI]), and the social and emotional impact of SUI (Incontinence Impact Questionnaire [IIQ]). | Sample size justified.
Duration of followup: 10 months | Loss of followup: none
Choe, 2000 ^623^ | 40 women with stress urinary incontinence and vaginal prolapse. | 1 Transvaginal antimicrobial mesh synthetic mesh; 2 Anterior vaginal wall slings | Subjective cure from stress urinary no involuntary loss of urine during physical activities incontinence objective curenegative stress test and no leakage in urodynamic exam. | Intention to treat not stated. Open label.
RCT to examine effects of transvaginal antimicrobial mesh and anterior vaginal wall slings on females stress urinary incontinence | Exclusion criteria: not reported. | | Self reported urinary incontinence using standardized Medical Epidemiologic and Social Aspects of Aging Questionnaire, and validated visual analog scale. | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 6 months | Loss of followup: none | | | Sample size not justified.
Kuo, 2001 ^624^ | 50 women with various types of stress urinary incontinence. | 1 Pubovaginal sling procedure using rectus fascia; 2 Pubovaginal sling procedure using polypropylene mesh Sling was placed at the level of the bladder neck and tied with sufficient tension to prevent urinary leakage without obstructing the bladder outlet. | Video urodynamics. | Intention to treat not stated. Open label.
RCT to examine effects of pubovaginal sling procedure using rectus fascia or polypropylene mesh on female stress urinary incontinence. | Exclusion criteria: Stress incontinence with a large cystocele or uterine prolapse. | | Type 2 stress incontinence: abdominal leak point pressure >90cm. H20 or significant urethral hypermobility. Type 3 stress incontinence: abdominal leak point pressure <60cm H20. Mixed type 2 to 3 stress incontinence abdominal leak point pressure. 60 and 90cm H20. | Randomization with random numbers table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 6 months | Loss of followup: none. | | | Sample size not justified.
Cholhan, 2004 ^625^ | 48 women with genuine stress urinary incontinence diagnosed with demonstrated loss of urine with increased abdominal pressure (cough, Valsalva) in the absence of detrusor contractions on multichannel urodynamic. | 1 Conventional suburethral sling; 2 Modified sling placed at the mid-urethra without tension | Multichannel urodynamic outcomes. Self reported urinary incontinence. | No intention to treat. Open label.
RCT to examine effects of conventional suburethral sling or modified sling on female genuine stress urinary incontinence. | Exclusion criteria: not reported. | | | Randomization with permuted blocks of 10. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
Duration of followup: 3 months | Loss of followup: none | | | Sample size justified.
Hilton, 1989 ^626^ | 20 women with urodynamically proven genuine stress incontinence with or without other urinary symptoms and previous treatments. | 1 Suburethral sling; 2 Stamey endoscopic bladder neck suspension | Self reported urinary incontinence and urodynamic and profilometry outcomes. | No intention to treat. Open label.
RCT to examine effects of suburethral sling or Stamey endoscopic bladder neck suspension on female genuine stress incontinence. | Exclusion criteria: not reported. | | | Randomization with random number list. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 3 months and 2 years. | Loss of followup: not reported. | | | Sample size not justified.
Tseng, 2005 ^627^ | 62 women with genuine stress incontinence (GSI) alone or combined with pelvic prolapse less than International Continence Society (ICS) stage II treated with anterior colporrhaphy with or without posterior colporrhaphy and with vaginal total hysterectomy with or without sacrospinous ligament fixation for pelvic prolapse greater than ICS stage II. | 1 Suprapubic arc sling procedure; 2 Tension-free vaginal taping by Ulmsten | Objective cure as pad weight 1g or less. Improvement as decreased >50% in urine loss. | Intention to treat not stated. Double blind (patients and examiners).
RCT to examine effects of suprapubic arc sling procedure or tension-free vaginal taping on female stress incontinence. | Exclusion criteria: Previous anti-incontinence surgery, pelvic prolapse >stage II | | Urodynamic outcomes including free flowmetry urethral pressure profilometry, filling (provocative) and voiding cystometry, and a 1-hour pad test. | Computer-generated randomization code. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 2 years | Loss of followup: none | | | Sample size justified.
Barbalias, 1997 ^628^ | 48 consecutive women with type III incontinence. | 1 Vesicourethral suspension by allogenic Goretex sling; 2 Vesicourethral suspension by indigenous rectus abdominis fascia sling | Cure as complete freedom from urinary stress incontinence. | Intention to treat not stated.
RCT to examine effects of Goretex pubovaginal sling or typical indigenous material graft made of rectal fascia on female stress urinary incontinence. | Exclusion criteria: not reported. | | Urodynamic outcomes. | Computer generated random codes. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 30 months | Loss of followup: none | | | Sample size not justified.
Laurikainen, 2007 ^629^ | 273 women with history of stress urinary incontinence, indication for surgical treatment of stress incontinence, positive cough stress test, detrusor Instability Score 7 or less. | 1 Retropubic tension-free vaginal polypropylene tape procedure by Ulmsten; 2 Transobturator tension-free vaginal polypropylene tape procedure by de Leval | Objective cure as a negative stress test. | No intention to treat. Open label.
RCT to examine effects of retropubic tension-free vaginal tape procedure or transobturator tension-free vaginal tape procedure on female urinary stress incontinence. | Exclusion criteria: Previous incontinence surgery, postvoid residual urine volume >100ml, lower urinary tract anomaly, current urinary tract infection or >3 urinary tract infection episodes within the past year, urogenital prolapse of more than second degree, body mass index >35kg/m2, previous radiation therapy of the pelvis, active malignancy, anticoagulant therapy, hemophilia, neurogenic disease which can be associated with bladder disorders, use of antiholinergic medication or duloxetine, patient immobilization. | | Self reported symptoms using Urinary Incontinence Severity Score, Detrusor Instability Score, a visual analog scale (VAS 0–100), Incontinence Impact | Central computer-generated randomization in a ratio of 1:1 in balanced blocks of 4. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 2 months | Loss of followup: 3.7% | | Questionnaire-Short Form, and Urogenital Distress Inventory-Short Form (UDI-6). | Sample size justified.
Ward, 200 ^630^ | 344 women with urodynamic stress incontinence unresponsive to pelvic floor muscle exercise, who had completed their family. | 1 Tension Free Tape procedure using the Gynecare TVT device by Ulmsten; 2 Colposuspension using either two or three sutures to support paravaginal fascia from the ileopectineal ligament on each side. | Objective cure of stress incontinence as negative 1-hour pad test (<1g change in weight). | Intention to treat.
RCT to examine the effects of tension-free vaginal tape or colposuspension on stress urinary incontinence. | Exclusion criteria: vaginal prolapse requiring treatment, previous surgery for incontinence or prolapse, neurologic disease, known bleeding diathesis or current anticoagulant therapy, allergy to local anesthetic, detrusor over-activity, and voiding difficulty (maximum flow <15ml/sec or voiding pressure >50cm/H2O or residual volume >100ml). | | Subjective cure using Short Form-36 health status questionnaire, the Bristol Female Lower Urinary Tract Symptoms questionnaire. | Open label.
Duration of follow up: 2 years | Loss of follow up: 15.7% | | The responses were combined and transformed to generate eight health dimensions; with a potential score of 0 to 100 - higher scores indicate better perceived health. | Randomization was computer generated using randomly varying block sizes of 4 and 6. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.

Table F126 Effects of vaginal tapes and sling procedures on urinary continence in women (events) (table is sorted by rate of urinary continence after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Definition of Continence | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Rafi, 2004 ^605^ * | Tension-free vaginal tape with Ulmsten's method and concomitant vaginal hysterectomy | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Objective assessment: cured at 24 months | 39 | 43 | 97.5 | 93.1 | 1.0 (1.0; 1.1)
N = 186
Lord, 2006 ^615^ | Tension-free vaginal tape | Suprapubic urethral support sling | Stress incontinence: objective cure | 150 | 155 | 97.3 | 97.4 | 1.0 (1.0; 1.0)
N = 313
Kuo, 2001 ^624^ | Pubovaginal sling procedure using rectus fascia | Pubovaginal sling procedure using polypropylene mesh | Urinary continence: cured | 23 | 26 | 95.8 | 100.0 | 1.0 (0.9; 1.1)
N = 50
Choe, 2000 ^623^ | Transvaginal antimicrobial mesh synthetic mesh | Anterior vaginal wall slings | Objective cure from stress urinary incontinence | 19 | 14 | 95.0 | 70.0 | 1.4 (1.0; 1.8) | 4 (2; 1,046) | 250 (1; 588)E
N = 40
Adamiak, 2002 ^608^ | Tension-free vaginal tape with local analgesia (injection of 0.5–0.75% lidocaine hydrochloride in subcutaneous tissue). | Tension-free vaginal tape with spinal analgesia ( 0.5% bupivacaine hydrochloride administered at L3–L4 or L4–L5 interspace) | Urinary continence (complete cure) | 61 | 34 | 93.8 | 97.1 | 1.0 (0.9; 1.1)
N = 103
Rafii, 2004 ^605^ | Tension-free vaginal tape with Ulmsten's method alone | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Objective assessment: cured at 24 months | 93 | 43 | 93.0 | 93.1 | 1.0 (0.9; 1.1)
N = 186
David-Montefiore, 2006 ^618^ | Retropubic sub urethral sling procedure | Transobturator sub urethral sling procedure | Dry | 39 | 43 | 92.9 | 93.5 | 1.0 (0.9; 1.1)
N = 88
Cholhan, 2004 ^625^ | Conventional sub urethral sling | Modified sling placed at the mid-urethra without tension | Cure from urinary stress incontinence | 19 | 24 | 92.0 | 89.0 | 1.0 (0.8; 1.2)
N = 48
Meshcia, 2004 ^631^ | Tension-free vaginal tape | Application of the endopelvic fascia | Stress continent during the postoperative cough provocation test | 23 | 14 | 92.0 | 56.0 | 1.6 (1.1; 2.4) | 3 (1; 13) | 360 (78; 767)E
N = 50
Wadie, 2005 ^607^ | Fascial sling with free ends of flap fixed by a 1-zero polyglactin suture and the sling is fixed to the underlying periurethral fascia using 4-zero polyglactin sutures at the 6 and 12 o'clock positions | Tension-free vaginal polypropylene tape | Urinary continence (cure) as complete dryness with no usage of pads, anti-incontinence surgery response score of 0 and negative stress test | 23 | 26 | 92.0 | 92.9 | 1.0 (0.8; 1.2)
N = 53
deTayrac, 2004 ^612^ | Tension-free vaginal tape | Transobturator sub urethral tape | Objective cure: negative stress test | 27 | 26 | 90.0 | 86.7 | 1.0 (0.9; 1.2)
N = 61
Arunkalaiv anan, 2003 ^617^ | Porcine dermal sling (pelvicol implant) by Barrington | Tension-free vaginal tape by Ulmsten | Self reported urinary continence (dry) | 66 | 58 | 89.2 | 85.3 | 1.0 (0.9; 1.2)
N = 142
Darai, 2007 ^622^ | Suburethral sling procedure with retropubic routes by Ulmsten | Suburethral sling procedure with transobturator routes by Delorme | Objective cure | 37 | 40 | 88.1 | 87.0 | 1.0 (0.9; 1.2)
N = 88
Rechberger, 2003 ^606^ | Monofilament tape inserted at the midurethra using the tension-free vaginal tape delivery instrument | Multifilament tape using the Intravaginal slingplasty delivery instrument | Urinary continence (cured) | 44 | 40 | 88.0 | 80.0 | 1.1 (0.9; 1.3)
N = 100
Lim, 2005 ^614^ | Suburethral slingplasty with tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Urinary continence: (cured) | 51 | 44 | 87.9 | 81.5 | 1.1 (0.9; 1.3)
N = 195
Lord, 2006 ^615^ | Tension-free vaginal tape | Suprapubic urethral support sling | Stress incontinence: subjective cure | 134 | 122 | 87.1 | 76.5 | 1.1 (1.0; 1.3) | 9 (63; 5) | 106 (16; 199)E
N = 313
Valpas, 2004 ^610^ | Tension-free vaginal tape under local anesthesia with polypropylene mesh tape placed under the midurethra. | Laparoscopic mesh colposuspensi on under general anesthesia (Hannah and Chin) | Negative stress test | 60 | 29 | 85.7 | 56.9 | 1.5 (1.2; 2.0) | 3 (2;11) | 289 (94; 540)E
N = 128
Meschia, 2006 ^616^ | Tension-free vaginal tape under local or epidural anesthesia | Intravaginal slingplasty under local or epidural anesthesia | Subjects cure from stress urinary incontinence: no urine loss during “stress” and failure as any reported leakage of urine during exertion | 80 | 68 | 84.2 | 71.6 | 1.2 (1.0; 1.4) | 8 (4; 159) | 126 (6; 266)E
N = 190 | | | Negative stress test | 79 | 65 | 83.2 | 68.4 | 1.2 (1.0; 1.4) | 7 (3; 46) | 147 (22; 295)E
Andonian, 2005 ^613^ | Suprapubic arch sling | Tension-free vaginal tape by Ulmsten | Objective cure (1-hour pad test <2g) | 34 | 41 | 83.0 | 95.0 | 0.9 (0.7; 1.0)
N = 84
Lim, 2005 ^614^ | Suburethral slingplasty with the tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with the Intravaginal sling multifilament threads | Stress urinary incontinence (cured) | 48 | 47 | 82.8 | 87.0 | 1.0 (0.8; 1.1)
N = 195
Meschia, 2006 ^616^ | Tension-free vaginal tape under local or epidural anesthesia | Intravaginal slingplasty under local or epidural anesthesia | Negative pad test pad test | 78 | 63 | 82.1 | 66.3 | 1.2 (1.0; 1.5) | 6 (35; 3) | 158 (29; 311)E
N = 190
Tseng, 2005 ^627^ | Suprapubic arc sling procedure | Tension-free vaginal taping by Ulmsten | Objective cure from stress urinary incontinence: pad weight 1g or less | 25 | 27 | 80.6 | 87.1 | 0.9 (0.7; 1.2)
N = 62
Lim, 2005 ^614^ | Suburethral slingplasty with the suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with the intravaginal sling multifilament threads | Stress urinary incontinence: (cured) | 45 | 47 | 77.6 | 87.0 | 0.9 (0.8; 1.1)
N = 195
Maher, 2005 ^620^ | Pubovaginal sling | Transurethral macroplastique | Subjectively cured | 17 | 19 | 77.3 | 82.6 | 0.9 (0.7; 1.3)
N = 45
Abdel-Fattah, 2004 ^621^ | Pelvicol pubovaginal sling | Tension-free vaginal tape | Dry | 56 | 53 | 75.7 | 77.9 | 1.0 (0.8; 1.2)
N = 142
Rafii, 2004 ^605^ | Tension-free vaginal tape with Ulmsten's method and concomitant vaginal hysterectomy | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Subjective assessment: cured at 24 months | 29 | 31 | 72.5 | 67.3 | 1.1 (0.8; 1.4)
N = 186
Lim, 2005 ^614^ | Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with Intravaginal sling multifilament threads | Urinary continence: (cured) | 42 | 44 | 72.4 | 81.5 | 0.9 (0.7; 1.1)
N = 195
Rafii, 2004 ^605^ | Tension-free vaginal tape with Ulmsten's method alone | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Subjective assessment: cured at 24 months | 72 | 31 | 72.0 | 67.3 | 1.1 (0.8; 1.4)
N = 186
Ward, 2004 ^630^ | Tension Free Tape procedure | Colposuspension | Objective cure as negative 1-hour pad test | 111 | 86 | 63.43 | 50.89 | 1.25 (1.03; 1.50) | 8 (56; 4) | 125 (18; 255)E
N = 344 | | | Subjective cure: no leakage under any circumstance | 44 | 34 | 25.14 | 20.12 | 1.25 (0.84; 1.85)
100% female | | | Subjective cure from stress leakage | 75 | 63 | 42.86 | 37.28 | 1.15 (0.89; 1.49)
Followup: 24 months
Lim, 2005 ^614^ | Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Urge incontinence (cured) | 24 | 18 | 41.4 | 33.3 | 1.2 (0.8; 2.0)
N = 195 | | | Urinary urgency (cured) | 20 | 20 | 34.5 | 37.0 | 0.9 (0.6; 1.5)
| Suburethral slingplasty with tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Urge incontinence (cured) | 19 | 18 | 32.8 | 33.3 | 1.0 (0.6; 1.7)
| | | Dysfunctional voiding (cured) | 8 | 8 | 13.8 | 14.8 | 0.9 (0.4; 2.3)
| Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Cured from intrinsic sphincter deficiency as maximum urethral closure pressure <20cm/H2O | 6 | 9 | 10.3 | 16.7 | 0.6 (0.2; 1.6)
Maher, 2005 ^620^ | Pubovaginal sling | Transurethral macroplastique | Objectively (cured) | 2 | 17 | 9.1 | 73.9 | 0.1 (0.0; 0.5) | 2 (1; 3) | 648 (391; 715)A
N = 45
Lim, 2005 ^614^ | Suburethral slingplasty with tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Cured from intrinsic sphincter deficiency as maximum urethral closure pressure <20cm/H2O | 3 | 9 | 5.2 | 16.7 | 0.3 (0.1; 1.1)
N = 195

* Case control study;

Bold - significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient = 1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F127 Effects of vaginal tapes and sling procedures on improvement of urinary incontinence in women (events) (table is sorted by rate of improvement after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Choe, 2000 ^623^ | Transvaginal antimicrobial mesh synthetic mesh | Anterior vaginal wall slings | Improvement in symptoms of stress urinary incontinence | 20 | 16 | 100.0 | 80.0 | 1.2 (1.0; 1.6)
N = 40
Barbalias, 1997 ^628^ | Vesicourethral suspension by allogenic Goretex sling | Vesicourethral suspension by indigenous rectus abdominis fascia sling | Cure or improvement in stress urinary incontinence | 16 | 26 | 100.0 | 81.3 | 1.2 (1.0; 1.5) | 5 (904; 3) | 188 (1; 373)E
N = 48
Dietz, 2005 ^619^ | Suprapubic arc sling | Intravaginal sling | Cured/improved for stress incontinence (%) | 42 | 35 | 95.5 | 77.8 | 1.2 (1.0; 1.5) | 6 (35; 3) | 177 (28; 352)E
N = 195 | | | Overall cure/improvement (%) | 41 | 37 | 93.2 | 82.2 | 1.1 (1.0; 1.3)
| Tensionless vaginal tape | Intravaginal sling | Cured/improved for stress incontinence (%) | 39 | 35 | 83.0 | 77.8 | 1.1 (0.9; 1.3)
| | | Overall cure/improvement (%) | 37 | 37 | 78.7 | 82.2 | 1.0 (0.8; 1.2)
Arunkalaivanan, 2003 ^617^ | Porcine dermal sling (pelvicol implant) by Barrington | Tension-free vaginal tape by Ulmsten | Improvement in urinary stress incontinence by 90–100% | 56 | 51 | 75.7 | 75.0 | 1.0 (0.8; 1.2)
N = 142
Dietz, 2005 ^619^ | Suprapubic arc sling | Intravaginal sling | Cured/improved for urge incontinence (%) | 30 | 32 | 68.2 | 71.1 | 1.0 (0.7; 1.3)
N = 195 | Tensionless vaginal tape | Intravaginal sling | Cured/improved for urge incontinence (%) | 30 | 32 | 63.8 | 71.1 | 0.9 (0.7; 1.2)
Lim, 2005 ^614^ | Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with Intravaginal sling multifilament threads | Urge incontinence pre and post symptom free | 23 | 32 | 39.7 | 59.3 | 0.7 (0.5; 1.0) | 5 (3; 115) | 196 (9; 323)A
N = 195 | | | Urge incontinence improved but not cured | 23 | 8 | 39.7 | 14.8 | 2.7 (1.3; 5.5) | 4 (2; 22) | 248 (46; 662)E
| | | Urinary urgency pre and post symptom free | 17 | 22 | 29.3 | 40.7 | 0.7 (0.4; 1.2)
Rafii, 2004 ^605^ | Tension-free vaginal tape with Ulmsten's method and concomitant vaginal hysterectomy | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Subjective assessment: improved at 24 months | 10 | 10 | 25.0 | 21.7 | 1.2 (0.5; 2.5)
N = 186
Lim, 2005 ^614^ | Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Urinary urgency Improved but not cured | 12 | 9 | 20.7 | 16.7 | 1.2 (0.6; 2.7)
N = 195
Rafii, 2004 ^605^ | Tension-free vaginal tape with Ulmsten's method alone | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Subjective assessment: improved at 24 months | 20 | 10 | 20.0 | 21.7 | 0.9 (0.5; 1.8)
N = 186
Tseng, 2005 ^627^ | Suprapubic arc sling procedure | Tension-free vaginal taping by Ulmsten | Objective improvement in stress urinary incontinence: decrease >50% in urine loss | 6 | 4 | 19.4 | 12.9 | 1.5 (0.5; 4.8)
N = 62
Lim, 2005 ^614^ | Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Stress urinary incontinence: Improved but not cured | 10 | 7 | 17.2 | 13.0 | 1.3 (0.5; 3.2)
N = 195 | Suburethral slingplasty with tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Urge incontinence Improved but not cured | 10 | 8 | 17.2 | 14.8 | 1.2 (0.5; 2.7)
| | | Stress urinary incontinence: Improved but not cured | 10 | 7 | 17.2 | 13.0 | 1.3 (0.5; 3.2)
Arunkalaivanan, 2003 ^617^ | Porcine dermal sling (pelvicol implant) by Barrington | Tension-free vaginal tape by Ulmsten | Improvement in urinary stress incontinence by 75–90% | 10 | 7 | 13.5 | 10.3 | 1.3 (0.5; 3.3)
N = 142
Darai, 2007 ^622^ | Suburethral sling procedure with retropubic routes by Ulmsten | Suburethral sling procedure with transobturator routes by Delorme | Improvement in stress urinary incontinence | 5 | 6 | 11.9 | 13.0 | 0.9 (0.3; 2.8)
N = 88
Arunkalaivanan, 2003 ^617^ | Porcine dermal sling (pelvicol implant) by Barrington | Tension-free vaginal tape by Ulmsten | Improvement in urinary stress incontinence <75% | 8 | 10 | 10.8 | 14.7 | 0.7 (0.3; 1.8)
N = 142
Rechberger, 2003 ^606^ | Monofilament tape inserted at the midurethra using tension-free vaginal tape delivery instrument | Multifilament tape using intravaginal slingplasty delivery instrument | Significant improvement in urinary incontinence | 5 | 9 | 10.0 | 18.0 | 0.6 (0.2; 1.5)
N = 100
Abdel-Fattah, 2004 ^621^ | Pelvicol pubovaginal sling | Tension-free vaginal tape | Improved incontinence | 7 | 3 | 9.5 | 4.4 | 2.1 (0.6; 8.0)
N = 142
David-Montefiore, 2006 ^618^ | Retropubic suburethral sling procedure | Transobturator suburethral sling procedure | Improved incontinence | 2 | 1 | 4.8 | 2.2 | 2.2 (0.2; 23.3)
N = 88
Adamiak, 2002 ^608^ | Tension-free vaginal tape with local analgesia (injection of 0.5–0.75% lidocaine hydrochloride in subcutaneous tissue) | Tension-free vaginal tape with spinal analgesia (0.5% bupivacaine hydrochloride administered at L3–L4 or L4–L5 interspace) | Improvement in urinary incontinence | 3 | 1 | 4.6 | 2.9 | 1.6 (0.2; 15.0)
N = 103
deTayrac, 2004 ^612^ | Tension-free vaginal tape | Transobturator suburethral tape | Objective improvement:- improvement of stress urinary incontinence but positive stress test | 1 | 3 | 3.3 | 10.0 | 0.3 (0.0; 3.0)
N = 61
Arunkalaivanan, 2003 ^617^ | Porcine dermal sling (pelvicol implant) by Barrington | Tension-free vaginal tape by Ulmsten | Self reported improved urinary continence | 2 | 6 | 2.7 | 8.8 | 0.3 (0.1; 1.5)
N = 142

Bold - significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F128 Effects of vaginal tape and sling procedures on risk and progression of urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Meschia, 2006 ^616^ | Tension-free vaginal tape under local or epidural anesthesia | Intravaginal slingplasty under local or epidural anesthesia | Incidence of overactive bladder symptoms | 8 | 10 | 8.4 | 10.5 | 0.8 (0.3; 1.9)
N = 190 | | | Incomplete emptying | 5 | 4 | 5.3 | 4.2 | 1.3 (0.3; 4.5)
| | | Overactive bladder symptoms | 24 | 27 | 25.3 | 28.4 | 0.9 (0.6; 1.4)
Lord, 2006 ^615^ | Tension-free vaginal tape | Suprapubic urethral support sling | Incidence of positive stress test | 1 | 1 | 0.6 | 0.6 | 1.0 (0.1; 16.4)
N = 313 | | | Incidence of urge urinary incontinence | 12 | 17 | 7.8 | 10.7 | 0.7 (0.4; 1.5)
| | | Objective leakage in stress test | 4 | 4 | 2.6 | 2.5 | 1.0 (0.3; 4.1)
| | | Persistent subjective symptoms of stress urinary incontinence | 19 | 36 | 12.3 | 22.6 | 0.5 (0.3; 0.9) | 10 (7; 48) | 103 (21; 152)A
| | | Protection use for stress urinary incontinence | 33 | 32 | 21.4 | 20.1 | 1.1 (0.7; 1.6)
| | | Stress incontinence: objective failure | 4 | 4 | 2.7 | 2.6 | 1.0 (0.3; 4.1)
| | | Subjective treatment failure | 20 | 37 | 12.9 | 23.5 | 0.6 (0.3; 0.9) | 9 (6; 51) | 106 (19; 155)A
| | | Urgency symptoms (overall) | 80 | 84 | 51.9 | 52.8 | 1.0 (0.8; 1.2)
| | | Urgency symptoms (persistent) | 65 | 70 | 42.2 | 44.0 | 1.0 (0.7; 1.2)
| | | Urge urinary incontinence (persistent) | 33 | 37 | 21.4 | 23.3 | 0.9 (0.6; 1.4)
| | | Urge urinary incontinence (overall) | 45 | 54 | 29.2 | 34.0 | 0.9 (0.6; 1.2)
deTayrac, 2004 ^612^ | Tension-free vaginal tape | Transobturator sub urethral tape | Incidence of urge urinary incontinence | 2 | 2 | 6.7 | 6.7 | 1.0 (0.2; 6.6)
N = 61 | | | Incidence of voiding difficulties | 5 | 7 | 16.7 | 23.3 | 0.7 (0.3; 2.0)
| | | No obstruction in uroflow | 19 | 17 | 63.3 | 56.7 | 1.1 (0.7; 1.7)
| | | Free Qmax 15 ml/s | 3 | 4 | 10.0 | 13.3 | 0.8 (0.2; 3.1)
Adamiak, 2002 ^608^ | Tension-free vaginal tape with local analgesia (injection of 0.5–0.75% lidocaine hydrochloride in subcutaneous tissue) | Tension-free vaginal tape with spinal analgesia (0.5% bupivacaine hydrochloride administered at L3–L4 or L4–L5 interspace) | Incidence of urge urinary incontinence | 4 | 2 | 6.2 | 5.7 | 1.1 (0.2; 5.6)
N = 103 | | | Urinary retention | 8 | 5 | 12.3 | 14.3 | 0.9 (0.3; 2.4)
Tseng, 2005 ^627^ | Suprapubic arc sling procedure | Tension-free vaginal taping by Ulmsten | Incidence of urge urinary incontinence | 5 | 2 | 16.1 | 6.5 | 2.5 (0.5; 11.9)
N = 62 | | | Incidence of urinary urgency | 5 | 3 | 16.1 | 9.7 | 1.7 (0.4; 6.4)
Cholhan, 2004 ^625^ | Conventional suburethral sling | Modified sling placed at the mid-urethra without tension | Incidence of urge urinary incontinence | 2 | 1 | 8.0 | 4.0 | 2.6 (0.2; 26.5)
N = 48
Darai, 2007 ^622^ | Suburethral sling procedure with retropubic routes by Ulmsten | Suburethral sling procedure with transobturator routes by Delorme | Incidence of urinary urgency | 6 | 4 | 15.1 | 7.7 | 1.6 (0.5; 5.4)
N = 88
Choe, 2000 ^623^ | Transvaginal antimicrobial mesh synthetic mesh | Anterior vaginal wall slings | Incidence of urinary urgency | 1 | 1 | 5.0 | 5.0 | 1.0 (0.1; 14.9)
N = 40
Abdel-Fattah, 2004 ^621^ | Pelvicol pubovaginal sling | Tension-free vaginal tape | Incidence of urinary urgency | 12 | 9 | 16.2 | 13.2 | 1.2 (0.6; 2.7)
N = 142
Kuo, 2001 ^624^ | Pubovaginal sling procedure using rectus fascia | Pubovaginal sling procedure using polypropylene mesh | Incidence of urinary urgency and mild urge incontinence | 2 | 1 | 8.3 | 3.8 | 2.2 (0.2; 22.4)
N = 50
Lim, 2005 ^614^ | Suburethral slingplasty with tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Increased bladder sensation (cured) | 9 | 4 | 15.5 | 7.4 | 2.1 (0.7; 6.4)
N = 195 | | | Stress urinary incontinence: pre and post symptom free | 3 | 4 | 5.2 | 7.4 | 0.7 (0.2; 3.0)
| | | Incontinence still present | 7 | 10 | 12.1 | 18.5 | 0.7 (0.3; 1.6)
| | | Urinary urgency (cured) | 20 | 20 | 34.5 | 37.0 | 0.9 (0.6; 1.5)
| | | Urinary urgency Improved but not cured | 22 | 9 | 37.9 | 16.7 | 2.3 (1.2; 4.5) | 5 (40; 2) | 213 (25; 583)E
| | | Urinary urgency pre and post symptom free | 15 | 22 | 25.9 | 40.7 | 0.6 (0.4; 1.1)
| | | Urge incontinence pre and post symptom free | 28 | 32 | 48.3 | 59.3 | 0.8 (0.6; 1.2)
| | | Acquired (de novo) | 4 | 5 | 6.9 | 9.3 | 0.7 (0.2; 2.6)
| | | Stress urinary incontinence: acquired (de novo) | 0 | 0 | 0.0 | 0.0
| | | Acquired (de novo) detrusor over activity | 2 | 2 | 3.4 | 3.7 | 0.9 (0.1; 6.4)
| | | Acquired (de novo) dysfunctional voiding | 3 | 2 | 5.2 | 3.7 | 1.4 (0.2; 8.0)
| | | Acquired (de novo) increased bladder sensation | 3 | 1 | 5.2 | 1.9 | 2.8 (0.3; 26.0)
| | | Acquired (de novo) intrinsic sphincter deficiency as maximum urethral closure pressure <20 cm/H2O | 10 | 4 | 17.2 | 7.4 | 2.3 (0.8; 7.0)
| Suburethral slingplasty with suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Detrusor over activity (cured) | 0 | 4 | 0.0 | 7.4 | 0.1 (0.0; 1.9)
| | | Increased bladder sensation (cured) | 7 | 4 | 12.1 | 7.4 | 1.6 (0.5; 5.3)
| | | Stress urinary incontinence: pre and post symptom free | 3 | 4 | 5.2 | 7.4 | 0.7 (0.2; 3.0)
| | | Incontinence still present | 16 | 10 | 27.6 | 18.5 | 1.5 (0.7; 3.0)
| | | Acquired (de novo) | 3 | 5 | 5.2 | 9.3 | 0.6 (0.1; 2.2)
| | | Stress urinary incontinence: acquired (de novo) | 0 | 0
| | | Acquired (de novo) detrusor over activity | 1 | 2 | 1.7 | 3.7 | 0.5 (0.0; 5.0)
| | | Acquired (de novo) dysfunctional voiding | 4 | 2 | 6.9 | 3.7 | 1.9 (0.4; 9.8)
| | | Acquired (de novo) increased bladder sensation | 2 | 1 | 3.4 | 1.9 | 1.9 (0.2; 20.0)
| | | Acquired (de novo) intrinsic sphincter deficiency as maximum urethral closure pressure <20cm/H2O | 3 | 4 | 5.2 | 7.4 | 0.7 (0.2; 3.0)
| | | Detrusor over activity (cured) | 3 | 4 | 5.2 | 7.4 | 0.7 (0.2; 3.0)
| | | Dysfunctional voiding (cured) | 4 | 8 | 6.9 | 14.8 | 0.5 (0.1; 1.5)
Ward, 2002 ^609^ | Tensionfree vaginal tape procedure | Colposuspen sion | Interfering with life overall | 48 | 28 | 27.4 | 16.6 | 1.7 (1.1; 2.5) | 9 (65; 4) | 109 (15; 250)E
N = 344 | | | Interfering with physical activity | 32 | 22 | 18.3 | 13.0 | 1.4 (0.9; 2.3)
| | | Interfering with social relationships | 19 | 17 | 10.9 | 10.1 | 1.1 (0.6; 2.0)
| | | Night time frequency (>0) | 99 | 83 | 56.6 | 49.1 | 1.2 (0.9; 1.4)
| | | Nocturnal enuresis | 14 | 11 | 8.0 | 6.5 | 1.2 (0.6; 2.6)
| | | Number with voiding disorder | 11 | 8 | 6.3 | 4.7 | 1.3 (0.5; 3.2)
| | | Number with genuine stress incontinence | 17 | 20 | 9.7 | 11.8 | 0.8 (0.4; 1.5)
| | | Number with unstable detrusor contractions | 12 | 13 | 6.9 | 7.7 | 0.9 (0.4; 1.9)
| | | Quantity of urine loss (>none) | 70 | 55 | 40.0 | 32.5 | 1.2 (0.9; 1.6)
| | | Straining | 25 | 25 | 14.3 | 14.8 | 1.0 (0.6; 1.6)
| | | Stress incontinence | 54 | 37 | 30.9 | 21.9 | 1.4 (1.0; 2.0)
| | | Unexplained incontinence | 27 | 17 | 15.4 | 10.1 | 1.5 (0.9; 2.7)
| | | Urge incontinence | 84 | 69 | 48.0 | 40.8 | 1.2 (0.9; 1.5)
| | | Urgency | 116 | 100 | 66.3 | 59.2 | 1.1 (1.0; 1.3)
| | | Wearing protection | 45 | 30 | 25.7 | 17.8 | 1.4 (1.0; 2.2)
| | | Ability to perform daily task | 25 | 19 | 14.3 | 11.2 | 1.3 (0.7; 2.2)
| | | Avoiding places or situations | 52 | 41 | 29.7 | 24.3 | 1.2 (0.9; 1.7)
| | | Bladder pain | 49 | 36 | 28.0 | 21.3 | 1.3 (0.9; 1.9)
| | | Changing outer clothing | 35 | 37 | 20.0 | 21.9 | 0.9 (0.6; 1.4)
| | | Dysuria | 38 | 29 | 21.7 | 17.2 | 1.3 (0.8; 2.0)
| | | Frequency of incontinent episodes (>never) | 72 | 66 | 41.1 | 39.1 | 1.1 (0.8; 1.4)
| | | Hesitancy | 75 | 70 | 42.9 | 41.4 | 1.0 (0.8; 1.3)
| | | History of retention | 8 | 6 | 4.6 | 3.6 | 1.3 (0.5; 3.6)
Choe, 2000 ^623^ | Transvaginal antimicrobial mesh synthetic mesh | Anterior vaginal wall slings | Mixed urinary incontinence | 1 | 4 | 5.0 | 20.0 | 0.3 (0.0; 2.0)
N = 40
Valpas, 2004 ^610^ | Tension-free vaginal tape under local anesthesia with polypropylene mesh tape placed under the midurethra | Laparoscopic mesh colposuspens ion under general anesthesia (Hannah and Chin) | Negative 48 hour pad test | 51 | 30 | 72.9 | 58.8 | 1.2 (0.9; 1.6)
N = 128 | | | Using pads | 0 | 6 | 0.0 | 11.7 | 0.1 (0.0; 1.0)
Zullo, 2005 ^632^ | Tension-free vaginal tape procedure plus postoperative vaginal estrogen: 1 estriol ovule (1mg) once daily for 1 month, then 2 ovules once weekly for 5 months | Tension-free vaginal tape procedure alone | Nocturia | 0 | 1 | 0.0 | 4.0 | 0.3 (0.0; 7.8)
N = 59 | | | Urgency of incontinence | 1 | 8 | 4.0 | 29.0 | 0.1 (0.0; 0.9) | 4 (4; 53) | 250 (19; 285)A
| | | Detrusor over activity symptoms | 1 | 1 | 4.0 | 4.0 | 1.0 (0.1; 15.2)
| | | Frequency of incontinence episodes | 2 | 5 | 7.0 | 18.0 | 0.4 (0.1; 1.9)
Rafii, 2004 ^605^ | Tension-free vaginal tape with Ulmsten's method alone | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Postoperative urinary leakage | 8 | 6 | 8.0 | 13.0 | 0.6 (0.2; 1.7)
N = 186 | | | De novo urinary urge symptoms at 1 month followup | 34 | 14 | 34.0 | 30.4 | 1.1 (0.7; 1.9)
| Tension-free vaginal tape with Ulmsten's method and concomitant vaginal hysterectomy | Tension-free vaginal tape with Ulmsten's method and pelvic floor reconstruction | Postoperative urinary leakage | 4 | 6 | 10.0 | 13.0 | 0.8 (0.2; 2.5)
| | | De novo urinary urge symptoms at 1 month followup | 6 | 14 | 15.0 | 30.4 | 0.5 (0.2; 1.2)
Meshcia, 2004 ^631^ | Tension-free vaginal tape | Plication of the endopelvic fascia | Self reported stress urinary incontinence | 1 | 9 | 4.0 | 36.0 | 0.1 (0.0; 0.8) | 3 (3; 15) | 320 (67; 355)A
N = 50
Hilton, 1989 ^626^ | Suburethral sling | Stamey endoscopic bladder neck suspension | Stress incontinence | 1 | 2 | 10.0 | 20.0 | 0.5 (0.1; 4.7)
N = 20
Maher, 2005 ^620^ | Pubovaginal sling | Transurethral Macroplastique | Stress incontinence | 4 | 0 | 18.2 | 0.0 | 9.4 (0.5; 164.8)
N = 45 | | | Urge incontinence | 7 | 4 | 31.8 | 17.4 | 1.8 (0.6; 5.4)
| | | Urgency in urination | 7 | 4 | 31.8 | 17.4 | 1.8 (0.6; 5.4)
| | | Voiding difficulty | 1 | 2 | 4.5 | 8.7 | 0.5 (0.1; 5.4)
Wadie, 2005 ^607^ | Fascial sling with free ends of flap fixed by a 1-zero polyglactin suture and the sling is fixed to the underlying periurethral fascia using 4-zero polyglactin sutures at the 6 and 12 o'clock positions | Tension-free vaginal polypropylene tape | Treatment failure - visible leakage on stress test and a total score of 6. | 2 | 2 | 8.0 | 7.1 | 1.1 (0.2; 7.4)
N = 53
Rechberger, 2003 ^606^ | Monofilament tape inserted at the midurethra using tension-free vaginal tape delivery instrument | Multifilament tape using intravaginal slingplasty delivery instrument | Urgency de novo | 8 | 4 | 16.0 | 8.0 | 2.0 (0.6; 6.2)
N = 100
Dietz, 2005 ^619^ | Suprapubic arc sling | Intravaginal sling | Voiding dysfunction (%) | 15 | 19 | 34.1 | 42.2 | 0.8 (0.5; 1.4)
N = 195 | Tensionless vaginal tape | | Voiding dysfunction (%) | 22 | 19 | 46.8 | 42.2 | 1.1 (0.7; 1.8)
Ward, 2002 ^609^ | Tension Free Tape procedure | Colposuspension | Urgency | 76 | 79 | 43.43 | 46.75 | 0.93 (0.74; 1.17)
N = 344 | | | Urge incontinence | 52 | 61 | 29.71 | 36.09 | 0.82 (0.61; 1.12)
24 months | | | Stress incontinence | 40 | 38 | 22.86 | 22.49 | 1.02 (0.69; 1.50)
| | | Unexplained incontinence | 21 | 27 | 12.00 | 15.98 | 0.75 (0.44; 1.28)
| | | Frequency incontinent episodes (>never) | 52 | 59 | 29.71 | 34.91 | 0.85 (0.63; 1.16)
| | | Quantity of urine loss (>none) | 52 | 54 | 29.71 | 31.95 | 0.93 (0.68; .28)
| | | Wearing protection | 32 | 36 | 18.29 | 21.30 | 0.86 (0.56; 1.32)
| | | Changing outer clothing | 32 | 33 | 18.29 | 19.53 | 0.94 (0.60; 1.45)
| | | History of retention | 4 | 4 | 2.29 | 2.37 | 0.97 (0.25; 3.80)
| | | Ability to perform daily tasks | 13 | 19 | 7.43 | 11.24 | 0.66 (0.34; 1.30)
| | | Avoiding places/situations | 25 | 26 | 14.29 | 15.38 | 0.93 (0.56; 1.54)
| | | Interfering with physical activity | 14 | 19 | 8.00 | 11.24 | 0.71 (0.37; 1.37)
| | | Interfering with social relationships | 9 | 12 | 5.14 | 7.10 | 0.72 (0.31; 1.67)
| | | Interfering with life overall | 20 | 25 | 11.43 | 14.79 | 0.77 (0.45; 1.34)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F129 Effects of vaginal tapes and sling procedures on perceived urinary incontinence in females (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Ward, 2002 ^609^ | The tension free vaginal tape procedure | Colposuspension | Voided volume per 24 hours (ml) | 1824.0 ± 206.0 | 1696.0 ± 234.7 | 0.6 (0.4; 0.8)
N = 344 | | | Episodes of nocturia | 1.0 ± 0.0 | 1.0 ± 0.0
| | | Leaks over 24 hours | 0.0 ± 0.0 | 0.0 ± 0.0
Valpas, 2004 ^610^ | Tension-free vaginal tape under local anesthesia with polypropylene mesh tape placed under the midurethra | Laparoscopic mesh colposuspensio n under general anesthesia (Hannah and Chin) | King's College Health Questionnaire Scores Incontinence Impact | | | -46.7 (4.35; 24.6)
N = 128 | | | King's College Health Questionnaire Scores Physical Limitations | | | -49.5 (1.06; 16.9)
| | | King's College Health Questionnaire Scores Social Limitations | | | -25.2 (1.04; 11.7)
| | | Urinary Incontinence Severity Score (0–20) | | | 1.6 (0.27; 2.94)
| | | Urge score (0–20) | | | 0.4 (-0.51; 1.5)
deTayrac, 2004 ^612^ | Tension-free vaginal tape | Transobturator suburethral tape | Daily activities (from 10 possible) | 8.9 ± 1.9 | 7.9 ± 3.0 | 0.4 (-0.1; 0.9) | 5.4 (-1.1; 11.9)
N = 61 | | | Self reported symptoms of urinary incontinence in visual analog scale ranging from 0 to 10 (0 - complete continence) | 2.7 ± 2.5 | 1.4 ± 2.8 | 0.5 (0.0; 1.0) | 35.0 (-1.7; 71.7)
| | | Visual Analog Scale (1–10) | | | 1.3 (0.65; 2.07)
Andonian, 2005 ^613^ | Suprapubic arch sling | Tension-free vaginal tape by Ulmsten | Subjective cure (IIQ scores) | 49.9 ± 25.6 | 45.3 ± 18.4 | 0.2 (-0.2; 0.6) | 0.5 (-0.5; 1.4)
N = 84
Zullo, 2005 ^632^ | Tension-free vaginal tape procedure plus postoperative vaginal estrogen: 1 estriol ovule (1mg) once daily for 1 month, then 2 ovules once weekly for the 5 months | Tension-free vaginal tape procedure alone | Self reported micturitions during 24 hours | 4.9 ± 2.0 | 6.0 ± 3.7 | -0.4 (-0.9; 0.2) | -6.2 (-15.0; 2.6)
N = 59
Wadie, 2005 ^607^ | Fascial sling with free ends of flap fixed by a 1-zero polyglactin suture and the sling is fixed to the underlying periurethral fascia using 4-zero polyglactin sutures at the 6 and 12 o'clock positions | Tension-free vaginal polypropylene tape | Urinary incontinence scores | 0.5 ± 3.0 | 0.5 ± 2.3 | 0.0 (-0.5; 0.5) | 0.0 (-107.9; 107.9)
N = 53
Abdel-Fattah, 2004 ^621^ | Pelvicol pubovaginal sling | Tension-free vaginal tape | Incontinence pads use/day | 2.6 ± 3.6 | 2.9 ± 2.0 | -0.1 (-0.4; 0.2) | -3.5 (-14.7; 7.7)
N = 142
Darai, 2007 ^622^ | Suburethral sling procedure with retropubic routes by Ulmsten | Suburethral sling procedure with transobturator routes by Delorme | Urinary Distress Impact Questionnaire, total score | 4.7 ± 10.0 | 1.2 ± 5.0 | 0.4 (0.0; 0.9) | 37.4 (2.1; 72.7)
N = 88 | | | Urinary Distress Impact Questionnaire: global discomfort | 1.2 ± 1.9 | 0.5 ± 0.9 | 0.5 (0.1; 0.9) | 95.6 (10.7; 180.5)
| | | Incontinence Impact Questionnaire, total score | 2.6 ± 16.0 | 0.0 ± 0.0
| | | Urinary Distress Impact Questionnaire: Emotional and social discomfort | 1.0 ± 1.7 | 0.5 ± 0.8 | 0.4 (0.0; 0.8) | 76.4 (-8.0; 160.8)
David-Montefiore, 2006 ^618^ | Retropubic suburethral sling procedure | Transobturator suburethral sling procedure | Quality of life scores (UDI scale) | 5.4 ± 20.3 | 5.7 ± 25.2 | 0.0 (-0.4; 0.4) | -0.2 (-7.6; 7.1)
N = 88 | | | Social and emotional status (IIQ scale) | 0.6 ± 3.2 | 6.1 ± 24.6 | -0.3 (-0.7; 0.1) | -5.0 (-11.9; 1.9)
Maher, 2005 ^620^ | Pubovaginal sling | Transurethral macroplastique | Median Short Urinary Distress Inventory score | 14.0 ± 57.3 | 11.0 ± 22.0 | 0.1 (-0.5; 0.7) | 0.6 (-4.7; 5.9)
N = 45 | | | Median Incontinence Impact Questionnaire score | 5.0 ± 53.3 | 9.0 ± 50.7 | -0.1 (-0.7; 0.5) | -0.9 (-7.4; 5.6)
Arunkalaivanan, 2003 ^617^ | Porcine dermal sling (pelvicol implant) by Barrington | Tension-free vaginal tape by Ulmsten | Incontinence pad use | 0.0 ± 5.3 | 0.0 ± 2.7 | 0.0 (-0.3; 0.3)
N = 142

Bold- significant differences in outcomes at 95% confidence level

Table F130 Effects of vaginal tapes and sling procedures on urinary incontinence in females (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Ward, 2002 ^609^ | Tension-free vaginal tape procedure | Colposuspension | Pressure transmission ratio (%):4th quarter | 29.0 ± 9.3 | 38.0 ± 4.0 | -1.2 (-1.5; -1.0) | -3.3 (-3.9; -2.7)
N = 344 | | | Post micturition residual (ml) | 0.0 ± 33.3 | 0.0 ± 23.3 | 0.0 (-0.2; 0.2
| | | Functional urethral length at rest (mm) | 30.0 ± 2.7 | 34.0 ± 2.0 | -1.7 (-1.9; -1.4) | -5.0 (-5.7; -4.3)
| | | Maximum urethral closure pressure at rest (mm) | 37.0 ± 10.0 | 46.0 ± 0.7 | -1.3 (-1.5; -1.0) | -2.7 (-3.2; -2.2)
| | | Maximum flow rate (ml/s) | 20.0 ± 3.3 | 20.0 ± 4.0 | 0.0 (-0.2; 0.2) | 0.0 (-1.1; 1.1)
| | | Maximum urethral closure pressure at cough (mm) | 45.0 ± 10.0 | 52.0 ± 23.3 | -0.4 (-0.6; -0.2) | -0.8 (-1.2; -0.3)
| | | Cystometric capacity (ml) | 450.0 ± 33.3 | 443.0 ± 39.3 | 0.2 (0.0; 0.4) | 0.0 (0.0; 0.1)
| | | Change in pad weight (g) | 0.0 ± 0.1 | 0.0 ± 0.2 | 0.0 (-0.2; 0.2)
| | | Functional urethral length at cough (mm) | 20.0 ± 4.0 | 25.0 ± 2.7 | -1.5 (-1.7; -1.2) | -5.9 (-6.8; -4.9)
| | | Maximum voiding pressure (cm/H2O) | 30.0 ± 5.3 | 30.0 ± 6.7 | 0.0 (-0.2; 0.2) | 0.0 (-0.7; 0.7)
| | | Volume at first desire to void (ml) | 236.0 ± 41.3 | 217.0 ± 48.0 | 0.4 (0.2; 0.6) | 0.2 (0.1; 0.3)
Barbalias, 1997 ^628^ | Vesicourethral suspension by allogenic | Vesicourethral suspension by indigenous rectus abdominis fascia sling. | Maximum flow rate | 11.4 ± 1.7 | 10.5 ± 1.8 | 0.5 (-0.1; 1.1) | 4.8 (-1.0; 10.6)
N = 48 | Goretex sling | | Maximum closure pressure | 43.5 ± 4.5 | 42.4 ± 3.9 | 0.3 (-0.3; 0.9) | 0.7 (-0.8; 2.1)
| | | First sensation of bladder filling | 180.4 ± 10.3 | 177.2 ± 9.4 | 0.3 (-0.3; 0.9) | 0.2 (-0.2; 0.5)
| | | Bladder capacity | 520.0 ± 58.1 | 490.0 ± 52.4 | 0.6 (-0.1; 1.2) | 0.1 (0.0; 0.2)
| | | Detrusor pressure at maximum flow | 35.7 ± 5.0 | 37.6 ± 5.9 | -0.3 (-0.9; 0.3) | -0.9 (-2.5; 0.7)
| | | Maximum detrusor pressure | 38.2 ± 4.2 | 37.9 ± 4.1 | 0.1 (-0.5; 0.7) | 0.2 (-1.4; 1.8)
| | | Residual urine | 82.0 ± 35.0 | 90.0 ± 45.0 | -0.2 (-0.8; 0.4) | -0.2 (-0.9; 0.5)
| | | Urethral functional length | 2.5 ± 0.1 | 2.3 ± 0.1 | 1.9 (1.2; 2.6) | 81.3 (50.4; 112.3)
deTayrac, 2004 ^612^ | Tension-free vaginal tape | Transobturator suburethral tape | Free Qmax (ml/s) | 24.4 ± 7.7 | 23.3 ± 8.0 | 0.1 (-0.4; 0.6) | 0.6 (-1.6; 2.8)
N = 61
Zullo, 2005 ^632^ | Tension-free vaginal tape procedure plus postoperative vaginal estrogen: 1 estriol ovule (1mg) once daily for 1 month, then 2 ovules once weekly for the 5 months | Tension-free vaginal tape procedure alone | Maximum cystometric capacity (ml) | 445.0 ± 43.4 | 439.0 ± 46.8 | 0.1 (-0.4; 0.7) | 0.0 (-0.1; 0.1)
N = 59 | | | Peak flow (ml/s) | 22.7 ± 3.2 | 23.6 ± 2.9 | -0.3 (-0.8; 0.2) | -1.2 (-3.5; 1.0)
| | | Flow time (ml/s) | 27.8 ± 4.1 | 27.9 ± 4.4 | 0.0 (-0.5; 0.5) | -0.1 (-2.0; 1.8)
| | | First voiding desire (ml) | 174.0 ± 21.4 | 148.0 ± 32.8 | 0.9 (0.4; 1.5) | 0.6 (0.3; 1.0)
| | | Detrusor pressure at peak flow (cm/H2O) | 18.6 ± 2.1 | 17.8 ± 1.9 | 0.4 (-0.1; 0.9) | 2.2 (-0.7; 5.2)
| | | Maximum urethral closure pressure (cm/H2O) | 73.6 | 75.9 | -0.5 (-1.0; 0.1) | -0.6 (-1.3; 0.1)
| | | | 3.5 | 6.3
| | | Urethral functional length (mm) | 25.0 ± 1.5 | 25.1 ± 1.7 | -0.1 (-0.6; 0.5) | -0.2 (-2.3; 1.8)
| | | Post void residual (ml) | 1.1 ± 4.2 | 1.3 ± 3.9 | 0.0 (-0.6; 0.5) | -3.8 (-44.1; 36.5)
Meshcia, 2004 ^631^ | Tension-free vaginal tape | Plication of the endopelvic fascia | First desire (minutes) | 175.0 ± 51.0 | 183.0 ± 59.0 | -0.1 (-0.7; 0.4) | -0.1 (-0.4; 0.2)
N = 50 | | | Very strong desire (ml) | 347.0 ± 67.0 | 343.0 ± 45.0 | 0.1 (-0.5; 0.6) | 0.0 (-0.1; 0.2)
| | | Average flow rate (ml/second) | 11.0 ± 6.0 | 14.0 ± 5.0 | -0.5 (-1.1; 0.0) | -3.9 (-7.9; 0.2)
| | | Voiding time (seconds) | 48.0 ± 178.0 | 31.0 ± 12.0 | 0.1 (-0.4; 0.7) | 0.4 (-1.4; 2.2)
| | | Functional length (mm) | 22.0 ± 6.0 | 25.0 ± 6.0 | -0.5 (-1.1; 0.1) | -2.0 (-4.3; 0.3)
Hilton, 1989 ^626^ | Suburethral sling | Stamey endoscopic bladder neck suspension | Rest: functional length, mm | 28.0 ± 5.5 | 26.0 ± 6.3 | 0.3 (-0.5; 1.2) | 1.3 (-2.1; 4.7)
N = 20 | | | Residual volume, ml | 3.0 ± 4.0 | 1.0 ± 3.0 | 0.6 (-0.3; 1.5) | 56.6 (-33.0; 146.1)
| | | First sensations, ml | 266.0 ± 147.0 | 301.0 ± 143.0 | -0.2 (-1.1; 0.6 | -0.1 (-0.4; 0.2)
| | | Cystometric capacity, ml | 584.0 ± 247.0 | 599.0 ± 132.0 | -0.1 (-1.0; 0.8) | 0.0 (-0.2; 0.1)
| | | Maximum voiding pressure, cm H20 | 28.0 ± 10.0 | 22.0 ± 16.0 | 0.4 (-0.4; 1.3) | 2.0 (-2.0; 6.1)
| | | Rest: total profile length, mm | 35.0 ± 9.2 | 35.0 ± 7.8 | 0.0 (-0.9; 0.9) | 0.0 (-2.5; 2.5)
| | | Rest: length to peak pressure, mm | 17.0 ± 7.3 | 17.0 ± 6.1 | 0.0 (-0.9; 0.9) | 0.0 (-5.2; 5.2)
| | | Rest: maximum urethral pressure, cm H20 | 47.0 ± 12.7 | 39.0 ± 18.9 | 0.5 (-0.4; 1.4) | 1.3 (-1.0; 3.6)
| | | Rest: maximum urethral closure pressure, cm H20 | 26.0 ± 14.4 | 26.0 ± 17.8 | 0.0 (-0.9; 0.9) | 0.0 (-3.4; 3.4)
| | | Stress: functional length, mm | 18.0 ± 5.2 | 14.0 ± 11.8 | 0.4 (-0.4; 1.3) | 3.1 (-3.2; 9.5)
| | | Stress: maximum urethral closure pressure, cm H20 | 26.0 ± 23.6 | 19.0 ± 15.9 | 0.3 (-0.5; 1.2) | 1.8 (-2.8; 6.5)
| | | Stress: length to peak pressure, mm | 9.0 ± 6.5 | 12.0 ± 8.4 | -0.4 (-1.3; 0.5) | -3.3 (-10.7; 4.1)
| | | Pressure transmission ratio, Q4,% | 57.0 ± 27.5 | 33.0 ±18.7 | 1.0 (0.1; 2.0) | 3.1 (0.3; 5.9)
| | | Peak flow rate, ml/s | 17.0 ± 8.0 | 30.0 ± 13.0 | -1.2 (-2.2; -0.2) | -4.0 (-7.2; -0.8)
Wadie, 2005 ^607^ | Fascial sling with free ends of flap fixed by a 1-zero polyglactin suture and the sling is fixed to the underlying periurethral fascia using 4-zero polyglactin sutures at the 6 and 12 o'clock positions | Tension-free vaginal polypropylene tape | Mean ml capacity | 389.4 ± 124.4 | 382.1 ± 75.9 | 0.1 (-0.5; 0.6) | 0.0 (-0.1; 0.2)
N = 53 | | | Detrusor pressure at maximum flow | 24.8 ± 14.2 | 30.6 ± 13.8 | -0.4 (-1.0; 0.1) | -1.4 (-3.1; 0.4)
| | | Maximum flow, ml/second | 19.4 ± 11.7 | 17.8 ± 8.3 | 0.2 (-0.4; 0.7) | 0.9 (-2.1; 3.9)
| | | Mean ml/cm/H2O compliance | 55.8 ± 31.7 | 69.2 ± 37.7 | -0.4 (-0.9; 0.2) | -0.6 (-1.3; 0.2)
| | | Post-void residual urine, ml | 8.8 ± 35.9 | 8.0 ± 22.1 | 0.0 (-0.5; 0.6) | 0.3 (-6.4; 7.1)
Lim, 2005 ^614^ | Suburethral slingplasty with the suprapubic arc sling macroporous monofilament threads | Suburethral slingplasty with the Intravaginal sling multifilament threads | Maximum urine flow rate | 4.0 ± 8.7 | 15.0 ± 22.0 | -0.7 (-1.0; -0.3) | -4.4 (-7.0; -1.9)
N = 195 | | | Average urine flow rate | 2.0 ± 6.7 | 8.0 ± 15.3 | -0.5 (-0.9; -0.1) | -6.4 (-11.1; -1.7)
| | | Average urine flow rate | 2.0 ± 6.7 | 12.0 ± 12.0 | -1.0 (-1.4; -0.6) | -8.7 (-12.0; -5.4)
| | | Maximum urine flow rate | 4.0 ± 8.7 | 9.0 ± 18.0 | -0.4 (-0.7; 0.0) | -4.0 (-8.1; 0.2)
Cholhan, 2004 ^625^ | Conventional sub urethral sling | Modified sling placed at the mid-urethra without tension | Peak CMG urinary flow rate, ml/second | 16.1 ± 11.2 | 18.1 ± 8.0 | -0.2 (-0.8; 0.4) | -1.2 (-4.3; 2.0)
N = 48 | | | Free urinary flow rate, ml/sec | 8.6 ± 5.3 | 9.8 ± 3.8 | -0.3 (-0.8; 0.3) | -2.7 (-8.6; 3.1)
| | | Cystometric bladder capacity, ml | 466.0 ± 185.0 | 429.0 ± 113.0 | 0.2 (-0.3; 0.8) | 0.1 (-0.1; 0.2)
| | | Voiding volume, ml | 341.0 ± 192.0 | 381.0 ± 120.0 | -0.3 (-0.8; 0.3) | -0.1 (-0.2; 0.1)
| | | Peak detrusor pressure, cmH20 | 55.2 ± 18.0 | 54.5 ± 15.0 | 0.0 (-0.5; 0.6) | 0.1 (-1.0; 1.1
| | | Urethral resistance cmH20ml-2s2 | 1.9 ± 2.6 | 0.7 ± 0.3 | 0.7 (0.1; 1.2) | 90.3 (10.0; 170.5)
| | | Functional urethral length, cm; sitting | 1.9 ± 0.6 | 2.1 ± 0.6 | -0.3 (-0.9; 0.2) | -15.9 (-43.2; 11.5)
| | | Cotton swab test (degrees), strain | 12.0 ± 13.0 | 18.0 ± 19.0 | -0.4 (-0.9; 0.2) | -2.0 (-5.2; 1.2)
| | | Cotton swab test (degrees), rest | 4.0 ± 12.0 | 9.0 ± 15.0 | -0.4 (-0.9; 0.2) | -4.0 (-10.4; 2.4)
| | | Maximum urethral closure pressure (cm/H2O), supine | 37.0 ± 17.0 | 36.0 ± 14.0 | 0.1 (-0.5; 0.6) | 0.2 (-1.4; 1.8)
| | | Maximum urethral closure pressure (cm/H2O), sitting | 39.0 ± 20.0 | 32.0 ± 15.0 | 0.4 (-0.2; 1.0) | 1.3 (-0.5; 3.1)
| | | Functional urethral length, cm; Supine | 2.3 ± 0.8 | 2.7 ± 0.6 | -0.6 (-1.2; 0.0) | -21.3 (-42.9; 0.2)
Tseng, 2004 ^627^ | Suprapubic arc sling procedure | Tension-free vaginal taping by Ulmsten | Maximum flow rate, (ml/second) | 18.7 ± 6.8 | 19.9 ± 7.9 | -0.2 (-0.7; 0.3) | -0.8 (-3.4; 1.7)
N = 62 | | | Average flow rate (ml/second) | 7.8 ± 3.0 | 9.0 ± 5.7 | -0.3 (-0.8; 0.2) | -3.0 (-8.5; 2.6)
| | | First desire to void (ml) | 114.8 ± 60.8 | 99.3 ± 63.1 | 0.3 (-0.2; 0.8) | 0.3 (-0.3; 0.8)
| | | Maximum cystometric capacity (ml) | 370.6 ± 133.3 | 341.4 ± 136.0 | 0.2 (-0.3; 0.7) | 0.1 (-0.1; 0.2)
| | | Maximum urethral closure pressure (resting)(cmH2O) | 51.5 ± 23.7 | 50.4 ± 16.9 | 0.1 (-0.4; 0.5) | 0.1 (-0.9; 1.1)
| | | Maximum urethral closure pressure (coughing) (cmH2O) | 46.7 ± 36.8 | 51.7 ± 54.7 | -0.1 (-0.6; 0.4) | -0.2 (-1.2; 0.8)
| | | Pressure transmission ratio | 72.9 ± 27.1 | 78.3 ± 27.6 | -0.2 (-0.7; 0.3) | -0.3 (-0.9; 0.4)
| | | Functional urethral length (resting) (mm) | 21.8 ± 5.2 | 17.6 ± 6.0 | 0.7 (0.2; 1.3) | 4.2 (1.3; 7.2)
| | | Functional urethral length (coughing) (mm) | 20.0 ± 7.6 | 19.3 ± 9.0 | 0.1 (-0.4; 0.6) | 0.4 (-2.2; 3.0)
Kuo, 2001 ^624^ | Pubovaginal sling procedure using rectus fascia | Pubovaginal sling procedure using polypropylene mesh | Post-void (ml) | 16.9 ± 26.7 | 29.6 ± 37.5 | -0.4 (-0.9; 0.2) | -1.3 (-3.2; 0.6)
N = 50 | | | Maximum urinary flow (ml/second) | 19.2 ± 10.6 | 16.2 ± 8.1 | 0.3 (-0.2; 0.9) | 2.0 (-1.5; 5.4)
| | | Capacity (ml) | 327.0 ± 101.0 | 253.0 ± 96.7 | 0.7 (0.2; 1.3) | 0.3 (0.1; 0.5)
| | | Bladder neck open time (second) | 9.1 ± 6.1 | 13.0 ± 11.3 | -0.4 (-1.0; 0.1) | -3.3 (-7.6; 1.1)
| | | Detrusor pressure (cm/H2O) | 18.4 ± 10.4 | 20.7 ± 9.0 | -0.2 (-0.8; 0.3) | -1.1 (-3.8; 1.5)
Lord, 2006 ^615^ | Tension-free vaginal tape | Suprapubic urethral support sling | Voiding volume, ml | 65.9 ± 139.7 | 2.0 ± 164.3 | 0.4 (0.2; 0.6) | 20.9 (9.7; 32.1)
N = 313 | | | Decrease in voiding volume | 25.0 ± 10.0 | 26.0 ± 9.3 | -0.1 (-0.3; 0.1) | -0.4 (-1.3; 0.5)
| | | Maximum flow rate, ml/s | 9.0 ± 6.7 | 6.0 ± 6.0 | 0.5 (0.2; 0.7) | 7.8 (4.1; 11.6)
| | | Decrease in maximum flow rate, ml/s | 9.0 ± 3.3 | 10.0 ± 4.0 | -0.3 (-0.5; 0.0) | -2.7 (-4.9; -0.5)
| | | Decrease in average flow rate, ml/s | 9.0 ± 21.3 | 4.0 ± 22.7 | 0.2 (0.0; 0.4) | 5.7 (0.1; 11.2)
| | | Average flow rate, ml/s | 4.0 ± 3.3 | 4.0 ± 3.3 | 0.0 (-0.2; 0.2) | 0.0 (-5.5; 5.5)
Lim, 2005 ^614^ | Suburethral slingplasty with tension-free vaginal tape macroporous monofilament threads | Suburethral slingplasty with intravaginal sling multifilament threads | Average urine flow rate | 2.0 ± 6.7 | 12.0 ± 12.0 | -1.0 (-1.4; -0.6) | -8.7 (-12.0; -5.4)
N = 195 | | | Maximum urine flow rate | 4.0 ± 8.7 | 9.0 ± 18.0 | -0.4 (-0.7; 0.0) | -4.0 (-8.1; 0.2)
| | | Average urine flow rate | 2.0 ± 6.7 | 8.0 ± 15.3 | -0.5 (-0.9; -0.1) | -6.4 (-11.1; -1.7)
| | | Maximum urine flow rate | 4.0 ± 8.7 | 15.0 ± 22.0 | -0.7 (-1.0; -0.3) | -4.4 (-7.0; -1.9)
Maher, 2005 ^620^ | Pubovaginal sling | Transurethral macroplastique | 1-hour pad test (g) | 5.0 ± 34.7 | 2.0 ± 12.0 | 0.1 (-0.5; 0.7) | 5.8 (-23.4; 35.1)
N = 45 | | | Maximum urethral closure pressure (cm/H2O) | 20.0 ± 17.3 | 26.0 ± 20.7 | -0.3 (-0.9; 0.3) | -1.2 (-3.5; 1.1)

Bold- significant differences in outcomes at 95% confidence level

Table F131 Surgical interventions on risk and progression of incontinence in women

Study | Participants | Clinical Interventions | Outcomes (Incidence) | Quality Issues
Colombo, 1996 ^633^ | 107 continent women admitted for surgical correction of severe urethrocystocele grade 2 or greater, a negative stress test with repositioning, and a positive cotton swab test. | 1 Cystopexy alone; 2 Cystopexy with posterior pubourethral ligaments plication | Urinary incontinence as occurrence both subjectively (patient's history) and objectively (positive stress test). | No intention to treat.
RCT to examine effects of cystopexy alone versus cystopexy with posterior pubourethral ligaments placation on prevention of urinary incontinence in women with genitourinary prolapse. | Exclusion criteria: urethrocystocele <grade 2, positive stress test with repositioning (potential stress incontinence), maximum urethral closure pressure less than 30cm/H2O, uninhibited detrusor contraction of any size during bladder filling, and previous retropubic anti-incontinence surgery. | | Stress incontinence at any time after surgery. Urethral Functional Length and Maximum Urethral Closure Pressure | Open label.
Duration of followup: 6 months, 1 and 2 years | Loss of followup: 3.7%, one patient (cystopexy alone) died on day 2 of a hemorrhagic complication due to a chronic hepatic dysfunction | | | Computer-generated randomization.
| | | | Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Brubaker, 2006 ^634^ | 322 women who did not report symptoms of stress incontinence and who chose to undergo sacrocolpopexy to treat prolapse. 22 women had prior surgery for incontinence, 60 women at baseline had stress incontinence and 89 had urge incontinence. | 1 Sacrocolpopexy with Burch colposuspensions.; 2 Sacrocolpopexy alone | Self reported stress incontinence and urge incontinence. | Intention to treat.
RCT to examine the effect of standardized Burch colposuspension in addition to abdominal sacrocolpopexy for the treatment of pelvic-organ prolapse on postoperative stress urinary incontinence in women without preoperative symptoms of stress incontinence. | Exclusion criteria: unable to undergo the Burch colposuspension on the basis of the assessment of the mobility of the urethrovesical junction. | | Maximum cystometric capacity | Single blind.
Duration of followup: 3 months after surgery | Loss of followup: none | | | Computer-generated, stratified by surgeon and intention to perform paravaginal repair randomization in blocks of various sizes. Allocation concealment adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Bump, 1996 ^635^ | 32 women with bladder neck hypermobility and stage III or IV pelvic organ prolapse. | 1 Needle colposuspension.; 2 Bladder neck endopelvic fascia plication as part of vaginal reconstructive surgery | Stress incontinence diagnosed based on self reported symptoms and positive stress test or abnormal urethral pressure profilometry or a positive direct visualization test immediately after catheters were removed in total absence of detrusor instability during urethrocystometry. | No intention to treat.
RCT to examine the effect of needle colposuspension or bladder neck endopelvic fascia plication as part of vaginal reconstructive surgery on urinary symptoms. | Exclusion criteria: not reported. | | | Open label.
Duration of followup: 6 weeks and 6 months | Loss of followup: 12.5% | | | Randomization with block size 4 or 6 chosen randomly.
| | | | Allocation concealment unclear. Baseline data not provided but states the same in groups. Sample size justified.
Meshcia, 2004 ^631^ | 50 patients with ≥ stage II anterior defect and a positive stress test result with prolapse reduction. | Vaginal hysterectomy, McCall culdoplasty, and cystocele repair for pelvic floor defects and | Self reported stress urinary incontinence, stress test, cotton swab test, and urodynamic outcomes. | Intention to treat not stated but all patients were analyzed. Open label. Computer-generated random list. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
RCT to examine the effect of tension-free vaginal tape or plication of the endopelvic fascia in women with severe genital prolapse. | Exclusion criteria: age >75 years, obesity (body mass index, >30kg/ml), diabetes mellitus, previous pelvic and anti-incontinence surgery, symptoms of SUI, cotton swab test <30 degrees, and uninhibited detrusor contraction of any size during bladder filling. | 1 Tension-free vaginal tape; 2 Plication of the endopelvic fascia | | Sample size justified.
Duration: 6 months after surgery | Loss of followup: none
Colombo, 1997, ^636^ | 109 patients with urethrocystocele of ≥grade 2 and a positive stress test result with prolapse reduction. | Cystopexy and | Self reported and clinical stress incontinence-positive stress test result with repositioning | Intention to treat not stated but all patients were analyzed. Open label. Computer-generated random list. Allocation concealment unclear. Baseline data differ by incontinence score, no adjustment reported. Sample size not justified.
RCT to examine effects of posterior pubourethral ligament plication or Pereyra suspension in patients with severe genitourinary prolapse and coexisting clinical or potential stress incontinence. | Exclusion criteria: urethrocystocele <2, negative stress test results with repositioning, maximum urethral closure pressure <30cm/H_2_O, occurrence of uninhibited detrusor contraction of any size during bladder filling, or previous retropubic anti-incontinence surgery. | 1 Posterior pubourethral ligament placation.; 2 Pereyra suspension
Duration: 6 months | Loss of followup: none
Jarvis, 2005 ^575^ | 60 women undergoing corrective surgery for pelvic organ prolapse and/or incontinence, able to follow verbal and written instructions in English. | Incontinence and/or prolapse surgeries and | Paper towel test, urinary symptom specific health and quality of life questionnaire, frequency/volume chart and pelvic floor muscle manometry. | Intention-to treat.
RCT to examine the effect of perioperative physiotherapy in women undergoing corrective surgery for pelvic organ prolapse and/or incontinence | Exclusion criteria: neuromuscular disorders or other significant medical problems, pelvic floor muscle intervention, tension-free vaginal tape. | 1 Preoperative physiotherapy; 2 No preoperative physiotherapy | Urinary symptoms (frequency, nocturia, urgency, urge, stress incontinence, coital incontinence, nocturnal enuresis, frequent urinary tract infections, bladder pain and difficulty passing urine) were estimated with self-reported scores, max score of 33 indicates high negative impact. | Single-blind.
Duration: 12 weeks | Loss of followup: 6.6% | | | Computer-generated randomization with balanced blocks of 20. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Roovers, 2004 ^637^ | 82 women undergoing surgical correction of uterine prolapse stages II–IV. | 1 Vaginal hysterectomy (combined with anterior and/or posterior colporraphy).; 2 Abdominal sacro-colpopexy (with preservation of the uterus) on urogenital function | Urogenital distress inventory (UDI) to measure discomfort of urinary incontinence symptoms Domain scores of the UDI (from 0 = lowest to 100 = highest discomfort) | Intention-to treat.
RCT to examine effects of vaginal hysterectomy and abdominal sacro-colpopexy on urogenital function in women undergoing surgical correction of uterine prolapse stages II–IV. | Exclusion criteria: the presence of adnexal mass, history of two or more abdominal pelvic surgical procedures, BMI>35kg/ml, inflammatory bowel or pelvic diseases, fecal incontinence. | | | Single-blind.
Duration: one year. | Loss of followup: 4.9% | | | Computer-generated randomization.
| | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Surgical treatments to treat female stress urinary incontinence
Sand, 2000 ^638^ | 36 women with stress incontinence, low-pressure urethra, and urethral hypermobility (straining cotton swab angle >30 degrees), maximum urethral closure pressure of ≤20cm/H_2_O in the sitting position, who failed previous surgery and medications. | 1 Burch procedures with 4 2-0 polytetrafluoroethylene sutures and tension placed on the periurethral sutures (modified Tanagho method).; 2 Suburethral sling with continuous polytetraflouroethylene strip from rectus fascia into retropubic space and beneath urethra at urethrovesical junction level | Objective cure of stress incontinence as no leakage of urine at maximum cystometric capacity during coughing or Valsalva maneuvers in sitting or standing position. Subjective cure as no loss of urine during any activity that increases intra-abdominal pressure. | Intention to treat not stated. Open label.
RCT to examine effects of modified Burch procedure or suburethral sling on females stress incontinence complicated by a low-pressure urethra. | Exclusion criteria: significant anterior pelvic support defects. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 3 months | Loss of followup: none | | | Sample size justified.
Demirci, 2001 ^639^ | 46 women with type I/type II genuine stress urinary incontinence. | 1 Burch colposuspension (Tanagho); 9 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy.; 2 McGuire's free-rectus fascial sling from inferior leaf of rectus fascia (5 to 6cm in length, 2cm center diameter and 1.5cm at either end; 8 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy. | Self reported urinary continence (dry) urodynamic outcomes. | No Intention to treat.
RCT to examine effects of pubovaginal sling or Burch colposuspension operations on females with type I/type II genuine stress urinary incontinence. | Exclusion criteria: preoperative detrusor instability, recurrent genuine stress urinary incontinence, severe pelvic prolapse, Valsalva leak point pressure >90 cm/H20. | | | Open label.
Duration of followup: 1 year | Loss of followup: 26% | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Culligan, 2003 ^640^ | 36 women with urodynamic stress incontinence, low-pressure urethra, urethral hypermobility. | 1 Burch colposuspension (Tanagho).; 2 Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension. | Objective cure of the stress incontinence as negative stress test and negative pad-weight test. Subjective cure of stress incontinence, no incontinence episodes on a 1-week voiding diary and voiding function studies | No Intention to treat.
RCT to examine effects of modified Burch procedure or sling procedure on female stress incontinence with a low-pressure urethra. | Exclusion criteria: significant anterior or apical pelvic floor support defects. | | | Open label.
Duration of followup: 72.6 months | Loss of followup: 18% | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Bai, 2005 ^641^ | 92 women with Grade 1 or 2 stress urinary incontinence. | 1 Burch colposuspension.; 2 Pubovaginal sling using autologous rectus muscle fascia.; 3 Tension-free vaginal tape | Self reported urinary continence. | Intention to treat not stated. Open label.
RCT to examine effects of Burch colposuspension, pubovaginal sling, and tension-free vaginal tape on female stress urinary incontinence. | Exclusion criteria: detrusor overactivity, urinary tract infection, intrinsic sphincter deficiency, pelvic organ prolapse >stage II. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 12 months | Loss of followup: not reported. | | | Sample size not. Justified.
Liapis, 2002 ^642^ | 72 women with genuine stress incontinence. | 1 Laparoscopic Burch colposuspension.; 2 Tension-free vaginal tape procedure | Objective cure as pad weight difference <1g, and improvement as a reduction of urine loss to less than 50% of urine loss prior to the operation - measured with 1 hour pad test | Intention to treat not stated. Open label.
RCT to examine effects of tension-free vaginal tape or Burch colposuspension on female genuine stress incontinence. | Exclusion criteria: prolapse >1 degree, previous surgical treatment of stress urinary incontinence, and detrusor instability. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 12–24 months | Loss of followup: not reported | | | Sample size not. justified
Paraiso, 2004 ^643^ | 72 females candidates for surgical correction of primary urodynamic stress incontinence, with abdominal leak-point pressures greater >60cm/H2O (or a positive cough stress test if the patient did not leak with the catheters in place); urethral hypermobility defined as maximal straining cotton-tipped swab angle >30°; and ability to undergo general anesthesia and laparoscopy. | 1 Burch colposuspension (Tanagho).; 2 Tension-free vaginal tape procedure. | Objective cure as no urinary leakage during urodynamic studies. Self reported urinary symptoms using Urogenital Distress Inventory with score range of 0 to 300, higher scores indicating greater distress. | Intention-to-treat Single blind.
RCT to examine effects of laparoscopic Burch colposuspension or tension-free vaginal tape procedure on female stress urinary incontinence. | Exclusion criteria: previous anti-incontinence surgery; detrusor overactivity on urodynamic studies defined by a rise in the true detrusor pressure not due to bladder compliance of >15cm/H2O; anterior vaginal wall prolapse to or beyond the hymen. | Concomitant procedures were performed in both groups. | Incontinence Impact Questionnaire with score range of 0 to 400, higher scores indicating greater adverse impact on quality of life. | Computer-generated randomization.
Duration of followup: 12 months. The trial was stopped early due to slow recruitment and lack of funding, prior to statistical analysis | Loss of followup: 8.3% | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Ustun, 2003 ^644^ | 46 women with genuine stress incontinence. | 1 Laparoscopic Burch colposuspension.; 2 Tension-free vaginal tape procedure | Urodynamic outcomes. | No intention to treat.
RCT to examine effects of laparoscopic Burch colposuspension or tension-free vaginal tape procedure on female genuine stress incontinence. | Exclusion criteria: not reported. | | Objective cure as no urinary leakage in urodynamic exam. | Open label.
Duration of followup: 18 months | Loss of followup: not reported. | | Subjective cure as no pad use and no urinary leakage in urodynamic exam | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified
El-Barky, 2005 ^645^ | 50 women with genuine stress incontinence | 1 Burch colposuspension.; 2 Tension-free vaginal tape procedure | Self reported stress urinary incontinence | No intention to treat.
RCT to examine effects of Burch colposuspension or tension-free vaginal tape procedure on female genuine stress incontinence | Exclusion criteria: high grade cystocele, previous surgical failure for stress incontinence, uninhibited detrusor contraction during bladder filling on urodynamic study, incompetent internal sphincters. | | | Open label.
Duration of followup: 6 months | Loss of followup: not reported | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified
Wang, 2003 ^646^ | 116 women with genuine stress incontinence. | 1 Modified Burch colposuspension.; 2 Tension-free vaginal taping | Objective cure as no demonstrable involuntary urine loss during any provocative maneuver in multichannel urodynamic tests in the absence of detrusor instability or pad weight 2g or less. Objective improvement as decrease in urine loss during pad test by >50% from baseline. | No intention to treat.
RCT to examine effects of modified Burch colposuspension tension-free vaginal taping on female genuine stress incontinence. | Exclusion criteria: pelvic prolapse, bladder outlet obstruction defined as presence of maximal flow rate of noninvasive uroflowmetry <2ml/second in repeated free uroflow studies combined with detrusor pressure at maximal flow >20cm/H2O or postvoid residual urine >100ml; previous anti-incontinence surgery. | | Subjective cure as no loss of urine during physical exercise. Subjective improvement as reduction by >50% in amount of preoperative leakage episode | Open label.
Duration of followup: 1 year | Loss of followup: 16.3% | | | Computer-generated randomization
| | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified
Colombo, 1996 ^647^ | 36 women with stress urinary incontinence. | 1 Burch colposuspension with placement of 2 couples of permanent polybutylate-coated polyester sutures.; 2 Abdominal paravaginal defect repair with 5–7 pairs of permanent braided silicone-coated polyester suture. | Cure as no incontinence episodes by history and no urine loss at stress test | Intention to treat not stated. Open label
RCT to examine effects of Burch colposuspension or abdominal paravaginal defect repair on female stress urinary incontinence. | Exclusion criteria: urethral sphincter weakness (maximum urethral closure pressure <20cm/H20), detrusor instability (occurrence of uninhibited detrusor contraction of any size during bladder filling), and previous failed abdominal anti-incontinence procedures. | | Profilometry outcomes. | Computer-generated randomization table.
Duration of followup: 6 months | Loss of followup: none. | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified
Gilja, 1998 ^648^ | 146 women operated on for stress urinary incontinence. | 1 Transvaginal Burch procedure.; 2 Burch retropubic urethropexy.; 3 Modified bladder neck suspension by Raz | Subjective cure from stress urinary incontinence as no leakage episodes and symptoms. | No Intention to treat.
RCT to examine effects of Raz, Burch and transvaginal Burch procedures on females stress urinary incontinence. | Exclusion criteria: prior gynecological or urological operation for urinary incontinence and a clear neuropathic condition. | | Objective cure as no urine loss in urodynamic exam. | Open label.
Duration of followup: 3 years. | Loss of followup: 28%. | | | Randomization with random numbers table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Berglund, 1996 ^649^ | 45 women with stress urinary incontinence. | 1 Retropubic urethrocystopexy.; 2 Pubococcygeal repair | Subjective cure as self reported urinary continence. | No Intention to treat.
RCT to examine effects of retropubic urethrocystopexy or pubococcygeal repair on females stress urinary incontinence. | Exclusion criteria: age>65 years, previous surgery for stress urinary incontinence, other gynecological diseases necessitating immediate surgical treatment, severe somatic diseases, e.g. diabetes mellitus, neurological diseases, heart failure, chronic kidney disease and psychiatric disorders. | | Objective cure as negative 1 hour pad test. | Open label.
Duration of followup: 12 months | Loss of followup: not reported | | | Randomization and allocation concealment not reported. Baseline data not reported.
| | | | Sample size not justified.
Lalos, 1993 ^650^ | 45 women with stress incontinence. | 1 Retropubic urethrocystopexy.; 2 Pubococcygeal repair | Subjective cure as self reported urinary continence. | No Intention to treat.
RCT to examine effects of retropubic urethrocystopexy or pubococcygeal repair on females stress urinary incontinence. | Exclusion criteria: age>65 years, previous surgery for stress urinary incontinence. | | Objective cure as negative 1 hour pad test. | Open label.
Duration of followup: 1 year | Loss of followup: 20% | | | Randomization and allocation concealment not reported. Baseline data not reported.
| | | | Sample size not justified.
Osman, 2003 ^651^ | 75 women with mixed urinary incontinence and negative cystometrogram for detrusor overactivity for >6 months | 1 Burch retropubic suspension (if Valsalva leak-point pressure >90cm/H20) with simple elevation of vaginal wall and periurethral fascia to 1/2way between original position of bladder neck and Cooper ligament Pubovaginal sling (if Valsalva leak-point pressure <90cm/H20) with minimal tension by McGuire.; 2 Oxybutynin hydrochloride 5mg 3 times/day | Self reported symptoms of urinary incontinence and urodynamic test | No intention to treat.
RCT to examine effects of anticholinergic treatment or surgery on female urinary incontinence. | Exclusion criteria: other treatment for incontinence for ≥3 months, non-sterile urine culture; cystometrogram positive for motor detrusor overactivity and detrusor pressure rise of >5cm/H2O); obstructed uroflow; previous surgery for incontinence; carcinoma in situ and interstitial cystitis. | | | Open label. Block randomization.
Duration of followup: 6 months | Loss of followup: 9.3% | | | Allocation concealment not reported. Baseline data not reported.
| | | | Sample size not justified.
Costantini, 2007 ^652^ | 66 consecutive continent patients with advanced prolapse with negative stress test before and after prolapse reduction. | 1 Sacropexy combined with a Burch colposuspension.; 2 Colposacropexy, no prophylactic colposuspension | Incidence of ex novo urinary incontinence measured with Ingelman | No Intention to treat.
RCT to examine effects of sacropexy combined with a Burch colposuspension on urinary incontinence in females with advanced prolapse. | Exclusion criteria: history of symptoms of urinary incontinence, positive symptoms questionnaire, and leakage during urodynamics tests. | | Sunderberg scale for incontinence, Urogenital Distress Inventory. | Open label.
Duration of followup: 40 months | Loss of followup: not reported | | Urodynamic outcomes. | Randomized block design. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Persson, 2002 ^653^ | 79 consecutive women presenting for evaluation of stress urinary incontinence symptoms urethral closing pressure ≥20cm/H2O, urethral functional length ≥25mm, hypermobility of the bladder neck (>45 degrees of down rotation at valsalva maneuver), and >5ml leaking on pad test. | 1 Laparoscopic colposuspension.; 2 Tension-free vaginal tape by Ulmsten | Objective cure as no leaking at postoperative pad-test, improvement as less than one third of the preoperative leakage | No Intention to treat.
RCT to examine effects of laparoscopic colposuspension or tension-free vaginal tape on female stress urinary incontinence. | Exclusion criteria: predominant urge incontinence, previous surgery for stress urinary incontinence, incontinence after previous vaginal repair, >2 grad uterovaginal prolapse, not having completed childbirth, need of gynecologic surgery, contraindication to incontinence surgery, increased risk for complications during general anesthesia or laparoscopic surgery, i.e. those with cardiovascular disease, known or suspected intra-abdominal adhesions, or abdominal obesity. | | | Open label.
Duration of followup: 1 year | Loss of followup: 13.9% | | | Randomization with self selected envelopes assigned to two treatments.
| | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Fatthy, 2001 ^654^ | 74 women with genuine stress incontinence. | 1 Laparoscopic Burch colposuspension with polypropylene suture.; 2 Open Burch colposuspension with polypropylene suture | Cure as no self reported urine loss, negative stress test and no leakage in urodynamic exam. | No Intention to treat.
RCT to examine effects of laparoscopic or open Burch colposuspension on female genuine stress incontinence. | Exclusion criteria: urinary tract infection, detrusor instability, under-active detrusor, intrinsic sphincter deficiency (Valsalva leak point pressure <90cm/H20), limited vaginal mobility, stages III and IV of vaginal prolapse, contraindications to surgery. | | Urodynamic outcomes. | Open label.
Duration of followup: 18 months | Loss of followup: 1.4% | | | Randomization with random numbers tables and permuted blocks. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Kitchener, 2006 ^655^ | 291 women with urodynamic stress urinary incontinence requiring colposuspension who failed previous anterior colporrhaphy. | 1 Open abdominal retropubic colposuspension.; 2 Laparoscopic colposuspension | Objective cure as negative 1-hour pad test (<1g/hour). | Intention to treat
RCT to examine effects of open or laparoscopic colposuspension on female stress urinary incontinence. | Exclusion criteria: comprised detrusor overactivity, previous retropubic surgery, severe obesity. | | Subjective cure as response of ‘perfectly happy/pleased’ to question 33 of the Bristol questionnaire (If you had to spend the rest of your life with your urinary symptoms as they are now, how would you feel?). | Open label. Central computer generated randomization with random permuted block sizes 2 and 4 with a dispersed block throughout the string, stratified by centre, age >50 years and previous bladder neck surgery. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
Duration of followup: 24 months | Loss of followup: 7.9% | | Quality of life using UK version of Short Form-36 (SF-36), the Bristol Female Lower Urinary Tract Symptom questionnaire, Symptom Severity and Symptom Impact Index and the EQ-5D. | Sample size justified
Cheon,2003 ^656^ | 90 women with urodynamically proven genuine stress incontinence. | 1 Laparoscopic colposuspension.; 2 Burch open colposuspension | Objective cure as dry during severe cough on urodynamic testing. | No Intention to treat.
RCT to examine effects of laparoscopic and open colposuspension in women with genuine stress incontinence. | Exclusion criteria: intrinsic sphincter deficiency, reduced vaginal capacity or fibrosis, previous anti-continence surgery or intrinsic sphincter deficiency (resting maximum urethral closure pressure <20cm/H2O or Valsalva leak point pressure <60cm/H2O). | | Self reported improvement in urinary incontinence symptoms. | Open label.
Duration of followup: 12 months | Loss of followup: not reported. | | | Computer generated random number table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Su, 1997 ^657^ | 92 patients with urodynamically proven genuine stress incontinence. | 1 Laparoscopic colposuspension.; 2 Open Burch colposuspension | Urodynamic outcomes. | Intention to treat not stated. Open label.
RCT to examine effects of laparoscopic or open colposuspensions on female genuine stress incontinence. | Exclusion criteria: reduced vaginal capacity or fibrosis, uterine prolapse or cystocele>1 Grade, detrusor instability, under-active detrusor or outflow obstruction, previous anti-incontinent surgery or hysterectomy. | | Objective cure as no leakage during urodynamic exam. | Randomization with computer generated random numbers table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
Duration of followup: 12 months | Loss of followup: none | | | Sample size justified.
German, 1994 ^658^ | 50 women with proven genuine stress incontinence. | 1 Modified needle suspension procedure.; 2 Vagina/obturator shelf procedure | Self reported urinary continence and de novo urge incontinence. | Intention to treat not stated. Open label.
RCT to examine effects of modified needle suspension procedure or vagina/obturator shelf procedure on female genuine stress incontinence. | Exclusion criteria: not reported. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 2 years | Loss of followup: not reported. | | | Sample size not justified.
Zullo, 2002 ^659^ | 60 women with mild or moderate genuine stress incontinence. | 1 Transperitoneal laparoscopic retropubic urethropexy using nonabsorbable sutures.; 2 Transperitoneal laparoscopic retropubic urethropexy using polypropylene mesh fixed with tacks or staples | Objective cure as no leakage during cough and Valsalva maneuver in standing position with bladder filled to maximum cystometric capacity during multichannel urodynamic exam. | No Intention to treat.
RCT to examine effects of transperitoneal laparoscopic urethropexy on female genuine stress incontinence | Exclusion criteria: sphincteric dysfunction (urethral pressure <20cm/H20 and Valsalva leak point pressure<60cm/H20), severe stress urinary incontinence. | | Subjective cure as self reported continence in Visual analog Scale (0=dry sensation, 10=severe leakage). | Open label.
Duration of followup: 12 months | Prolapse >2 grade, previous pelvic or incontinence surgery, severe abdomino-pelvic infection, extensive abdominal adhesions, detrusor instability, other gynecological diseases, BMI>30kg/ml. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| Loss of followup: 6.7% | | | Sample size justified.
Colombo, 2000 ^660^ | 71 women undergoing surgery for primary genuine stress incontinence and concurrent grade 2 or 3 cystocele (descending at or outside the vaginal introitus) and positive cotton swab test. | 1 Burch colposuspension with abdominal hysterectomy.; 2 Anterior colporrhaphy with vaginal hysterectomy | Subjective cure as no incontinence episodes. | No Intention to treat.
RCT to examine effects of Burch colposuspension or the anterior colporrhaphy in women with both stress urinary incontinence and advanced anterior vaginal wall prolapse. | Exclusion criteria: detrusor instability, previous anti-incontinence or prolapse surgery (retropubic or vaginal), concomitant pelvic diseases requiring laparotomy, medical conditions with a high risk of abdominal surgery. | | Objective cure as negative stress test result. | Open label.
Duration of followup: 14 years | Loss of followup: 4.2% | | | Computer generated random numbers table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Quadri, 1999 ^661^ | 30 women with stress urinary incontinence and low pressure (maximum urethral closure pressure of ≤20cm/H_2_O throughout its entire length) and hypermobility of the urethra (difference of >30 degrees between results of the cotton swab test performed in the supine position at rest and during stress and as a straining angle of >30 degrees from the horizontal). | 1 Burch colposuspension.; 2 Marshall-Marchetti-Krantz urethropexies with videourethroscopic control | Subjective cure as no incontinence episodes. | Intention to treat not stated. Open label.
RCT to examine effects of Burch colposuspension or Marshall-Marchetti-Krantz urethropexy with videourethroscopic control on stress urinary incontinence in females with low pressure and hypermobility of the urethra. | Loss of followup: none | | Objective cure as negative stress test result. | Computer-generated random numbers.
Duration of followup: 12 months | | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Colombo, 1994 ^662^ | 80 women with moderate or severe genuine stress urinary incontinence. | 1 Burch colposuspension.; 2 Modified Marshall-Marchetti-Krantz urethropexy | Subjective cure as no incontinence episodes by history. | No Intention to treat.
RCT to examine effects of Burch colposuspension or modified Marshall-Marchetti-Krantz urethropexy on female genuine stress urinary incontinence. | Exclusion criteria: urethral sphincter weakness (maximum urethral closure pressure <30cm/H_2_O), detrusor instability (occurrence of uninhibited detrusor contraction of any size during bladder filling), prolapse of genitourinary tract ≥ 2°, urethral diverticula, urogenital fistulas, and previous failed abdominal anti-incontinence procedures. | | Objective cure as no urine loss at stress test. | Open label.
Duration of followup: 2–7 years, median 3 years. | Loss of followup: none. | | Subjective improvement as clinical score of incontinence decreased from 8 to ≤4 or from 4 to ≤2. | Computer-generated random assignment.
| | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Bergman, 1995 ^663^ | 127 consecutive women with stress urinary incontinence. | 1 Anterior colporrhaphy with Kelly plication.; 2 Modified Pereyra needle urethropexy using inclusions of the pubourethral ligaments and endopelvic fascia at the level of the proximal urethra and bladder neck.; 3 Burch urethropexy included the basic principles of the Tanagho modification: (1) minimal dissection within 2cm of the urethrovesical junction and urethra, (2) placement of sutures through full thickness of shiny white paravaginal fascia, (3) use of two sutures on each side, one opposite to the urethrovesical junction and another at the level of the midurethra, (4) removal of adipose tissue lateral to the sutures to stimulate fibrosis, and (5) facilitating typing of sutures to the Cooper ligament with intravaginal fingers elevating the anterior vaginal wall. | Subjective cure as absence of complaint of persistent incontinence. | No Intention to treat.
RCT to examine effects of Kelly plication, modified Pereyra needle suspension, or Burch urethropexy on female stress urinary incontinence. | Exclusion criteria: failure of previous anti-incontinence procedures, gynecologic disease necessitating hysterectomy, other gynecologic operations, or other indications for laparotomy. | | Objective cure as no evidence of loss of urine on cough profile during urodynamic evaluation at maximum cystometric capacity. | Open label.
Duration of followup: 5 years | Loss of followup: 26.7% | | | Randomization with computer generated random numbers table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified
Kammerer-Doak, 1999 ^664^ | 35 women with stress incontinence with grading of prolapse (grades 0–4). | 1 Burch retropubic urethropexy by Tanagho.; 2 Modified anterior colporrhaphy | Objective cure as absence of urine loss during cough and valsalva maneuver in the supine and standing positions, with the bladder filled to maximal cystometric capacity. | No Intention to treat.
effects of Burch retropubic urethropexy or modified anterior colporrhaphy on female genuine stress urinary incontinence. | Exclusion criteria: incontinence of neurological origin, detrusor instability, history of previous radical pelvic surgery, pelvic radiation, intrinsic sphincteric deficiency (low abdominal leak point and maximal urethral closure pressures <65 and <20cm/H20) and history of interstitial cystitis or urethral syndrome. | | Multichannel urodynamic outcomes. 20-minute pad test, and subjective grading of incontinence severity with questionnaires (0 =none, 4 = more than one daily), number of incontinent episodes (0 = none, 6 = with every cough, sneeze, or laugh) and self assessment score (1 =dry, 10 = severe leakage), and overall quality of life according to the Incontinence Impact Questionnaire | Double blind.
Duration of followup: 1 year | Loss of followup: 5.7% | | | Computer-generated randomization table.
| | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization except age and post menopausal status.
| | | | Sample size not justified
Bergman, 1989 ^665^ | 127 consecutive patients with urodynamic genuine stress incontinence. | 1 Anterior colporrhaphy with Kelly placation.; 2 Modified Pereyra needle urethropexy using inclusions of the pubourethral ligaments and endopelvic fascia at the level of the proximal urethra and bladder neck.; 3 Burch urethropexy included the basic principles of the Tanagho modification: (1) minimal dissection within 2cm of urethrovesical junction and urethra, (2) placement of sutures through full thickness of shiny white paravaginal fascia, (3) use of two sutures on each side, one opposite to the urethrovesical junction and another at the level of the midurethra, (4) removal of adipose tissue lateral to sutures to stimulate fibrosis, and (5) facilitating typing of sutures to the Cooper ligament with intravaginal fingers elevating the anterior vaginal wall | Subjective cure as absence of complaint of persistent incontinence. | No Intention to treat.
RCT to examine effects of anterior colporrhaphy, revised Pereyra procedure, or Burch retropubic urethropexy on female genuine stress incontinence. | Exclusion criteria: other gynecological diseases necessitating hysterectomy, previous anti incontinence surgery, other indications for laparotomy. | | Objective cure as no evidence of loss of urine on cough profile during urodynamic evaluation at maximum cystometric capacity | Open label.
Duration of followup: 1 year. | Loss of followup: 5.5% | | | Randomization with computer generated random numbers table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Persson, 2000 ^666^ | 161 women with primary stress urinary incontinence, with normal urethral closing pressure and hypermobility of the bladder neck. | 1 Laparoscopic Burch colposuspension using one double-bite of polytetrafluoroethylene sutures placed on each side of the urethra under transperitoneal video laparoscopy.; 2 Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoroethylene sutures placed on each side of the urethra under transperitoneal video laparoscopy | Objective cure as negative pad test. Improvement as maximal one third of preoperative leaking volume on pad test. | No intention to treat.
RCT to examine effects of laparoscopic Burch colposuspension using one double-bite or two single-bite sutures on each side of the urethra on female stress urinary incontinence. | Exclusion criteria: urge incontinence, stress incontinence due to low urethral closing pressure (< 20cm/H2O), uterovaginal descent > grade 1 cystocele, incontinence after previous vaginal repair, recurrent incontinence, at increased risk for general anesthesia (i.e.), significant respiratory or cardiac disease, former complications attributable to general anesthesia, age >70 years old) and surgical complications (BMI>35kg/m2), known or suspected intra-abdominal adhesions, history of complications with laparoscopic surgery. | | Failure as > one third of preoperative leaking volume on pad test. Subjective cure rate as no reported leakage. | Open label.
Duration of followup: 1 year | Loss of followup: 2.5% | | | Randomization 1:1 with random numbers table.
| | | | Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified
Zullo, 2001 ^667^ | 60 women with mild or moderate genuine stress incontinence. | 1 Transperitoneal laparoscopic Burch procedure using nonabsorbable sutures.; 2 Transperitoneal laparoscopic Burch procedure using Prolene mesh fixed with tacks or staples | The subjective self reported urine loss on a visual analog scale graded from 0 (dry sensation) to 10 (severe leakage). | No Intention to treat.
RCT to examine effects of 2 transperitoneal laparoscopic Burch procedures on female genuine stress incontinence. | incontinence. Exclusion criteria: severe genuine stress incontinence (loss of urine with minimal physical activity), prolapse >2°, previous pelvic or anti-incontinence surgery, history of severe abdomino-pelvic infections or known extensive abdomino-pelvic adhesions, detrusor instability and/or intrinsic sphincter dysfunction, presence of other gynecologic pathologies (e.g., fibroids, ovarian cysts), BMI>30kg/ml. | | Subjective failure as a postoperative visual analog scale value equal to or higher than that obtained before surgery. | Single blind.
Duration of followup: 1 year | Loss of followup: 11.7% | | The objective cure failure as involuntary loss of urine during cough and Valsalva maneuver in the standing position with the bladder filled to maximal cystometric capacity during clinical observation or abnormal urodynamic tests. | Computer-generated randomization list.
| | | | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified
Ankardal, 2005 ^668^ | Women with genuine stress urinary incontinence or mixed incontinence with a predominantly stress component. | 1 Open Burch colposuspension using sutures.; 2 Laparoscopic colposuspension using sutures.; 3 Laparoscopic colposuspension using mesh and staples | 48-hour frequency-volume chart, a 48-hour pad test and a standardized stress test. | No intention to treat.
RCT to examine effects of open Burch colposuspension using sutures with laparoscopic colposuspension using sutures and laparoscopic colposuspension using mesh and staples on female stress UI. | Exclusion criteria: recurrent incontinence, detrusor instability diagnosed during filling cystometry, other gynaecologic surgery, e.g. hysterectomy or anterior colporaphia. | | Cure was defined as a urinary leakage <8g/24 hours. | Open label.
Duration of followup: 1 year | Loss of followup: 1.4% | | Stress test cure was defined as urinary leakage <5g. | Randomization with block ratio 2:1:2.
| | | The patients' degree of overall satisfaction regarding the result of the operation was also estimated using a VAS scale (0 = lowest degree of satisfaction and 100 = maximum satisfaction). | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified
Ankardal, 2004 ^669^ | 240 women with genuine stress urinary incontinence or mixed incontinence with a predominant stress component. | 1 Open Burch colposuspension using sutures.; 2 Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | Objective and subjective cure rates from 48-hour frequency-volume chart, a 48-hour pad test and a subjective assessment of the woman's incontinence and quality of life( Visual analog scale graded with maximum score of 100 for maximum bother) | No intention to treat.
RCT to examine effects of open Burch colposuspension using sutures or laparoscopic colposuspension using mesh and staples on female stress urinary incontinence | Exclusion criteria: recurrent incontinence, need of additional gynecological surgery, extremely large 24 hours urinary volumes. | | | Open label. Central randomization with random numbers table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
Duration of followup: 1 year | Loss of followup: 2.1% | | | Sample size justified
Ross, 1996 ^670^ | 69 previously untreated women with genuine stress incontinence and hyper mobile urethrovesical junction. | 1 Laparoscopic Burch procedure with sutures for bladder neck elevation.; 2 Laparoscopic Burch procedure with mesh and staples for bladder neck elevation | Objective cure as negative stress test. | No intention to treat.
RCT to examine effects of laparoscopic Burch procedure with mesh and staples or suture technique on female genuine stress incontinence. | Exclusion criteria: previous incontinence surgery, detrusor instability, inferred intrinsic sphincter dysfunction. | | | Open label.
Duration of followup: 1 year | Loss of followup: for cure rate not reported. Urodynamic outcomes reported in 30%. | | | Randomization with random numbers table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Klarskov, 1986 ^671^ | 50 consecutive female patients with genuine urinary stress incontinence | 1 Pelvic floor training program 5 times/week guided by trained physiotherapists.; 2 Surgery: Burch colposuspension for anterior suspension defect. Vaginal repair for posterior bladder descent. | Self reported urinary incontinence and cystometric outcomes. | No intention to treat.
RCT to examine effects of pelvic floor training program or surgery on female genuine urinary stress incontinence. | Exclusion criteria: previous surgery or pelvic floor training, significant urge incontinence, need of other gynecological surgery (prolapse, hysterectomy), mental impairment. | | | Open label.
Duration of followup: 4 months | Loss of followup: not reported. 14 patients did not have urodynamic exam. | | | Randomization and allocation concealment not reported. Baseline data not reported.
| | | | Sample size not justified
Albo, 2007 ^672^ | 655 women with predominant stress urinary incontinence for at least 3 months, positive standardized urinary stress test and urethral hyper mobility. | 1 Burch colposuspensions.; 2 Pubovaginal sling, using autologous rectus fascia. Key elements of the two surgical procedures were standardized among all participating surgeons (the use of preoperative antibiotics, skin-incision length, number and type of Burch sutures, fascial-sling length and width, and cystoscopic evaluation of the bladder). | Overall success as no self-reported symptoms of urinary incontinence, an increase <15g in pad weight during a 24-hour pad test, no incontinence episodes recorded in a 3-day diary, a negative urinary stress test (no leakage noted on examination during cough and Valsalva maneuvers at a standardized bladder volume of 300ml), and no retreatment for urinary incontinence. Incidence if urge incontinence 6 weeks after surgery. | No Intention to treat.
RCT of “The Stress Incontinence Surgical Treatment Efficacy Trial” to examine effects of pubovaginal sling, using autologous rectus fascia, or Burch colposuspension on female stress incontinence. | Exclusion criteria: not reported. | | Patient satisfaction assessed with the question; (“How satisfied or dissatisfied are you with the result of bladder surgery related to urine leakage?”). 5 response options: from “completely satisfied” to “completely dissatisfied.” | Open label. Central randomization using permuted-block randomization schedule with stratification according to clinical site. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 24 months | Loss of followup: 21% | | | Sample size justified
Carey, 2006 ^673^ | 200 women with urodynamic stress incontinence who failed conservative therapy. | 1 Laparoscopic Burch colposuspension; 2 Open Burch colposuspension by Tanagho with 2 polyester sutures in each side and third suture if a cystocele was present | Cure as absence of USI at 6 months following surgery. | Intention-to-treat.
RCT to examine the effects of laparoscopic Burch colposuspension and open Burch colposuspension on urinary stress incontinence. | Exclusion criteria: previous retropubic continence surgery, maximum urethral closure pressure <20cm/H2O; medically unsuitable for laparoscopic or open surgery; major degrees of coexisting pelvic organ prolapse, requiring surgery other than a simple rectocele repair. | | Self reported quality of life using. The Short Form-36 (SF-36) with lower scores for better general, physical, and mental health; the Short Urinary Distress Inventory (SUDI) and Short Incontinence Impact Questionnaire (SIIQ) | Single blind.
Duration of follow up: 6 months | Loss of follow up: 12.5% | | | Computer generated randomization lists with a block size of 6, stratified for each centre and for women undergoing concomitant rectocele repair for symptomatic rectocele. Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.

Table F132 Effects of surgical interventions on improvement of urinary incontinence in females (events) (table sorted by rate of improvement after active group treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Cheon, 2003 ^656^ | Laparoscopic colposuspension | Burch open colposuspension | Subjective improvement in stress urinary incontinence | 38 | 37 | 80.9 | 86.0 | 0.9 (0.8; 1.1)
N = 90
Persson, 2000 ^666^ | Laparoscopic Burch colposuspension using one double-bite of polytetrafluoroet hylene sutures placed on each side of the urethra under transperitoneal video laparoscopy | Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoroethylene sutures placed on each side of the urethra under transperitoneal video laparoscopy | Subjective improvement | 25 | 6 | 32.1 | 7.2 | 4.4 (1.9; 10.2) | 4 (15; 1) | 248 (67; 667)E
N = 161
Ankardal, 2004 ^669^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | Improvement in Visual analog scale | 37 | 62 | 30.8 | 51.7 | 0.6 (0.4; 0.8) | 5 (3; 11) | 208 (92; 293)A
N = 240
Ankardal, 2005 ^668^ | Open Burch colposuspension using sutures | Laparoscopic colposuspension using mesh and staples | Improvement in Visual analog scale | 24 | 19 | 30.4 | 35.8 | 0.8 (0.5; 1.4)
N = 121 | | | Improvement in Visual analog scale | 24 | 41 | 30.4 | 77.4 | 0.4 (0.3; 0.6) | 2 (2; 3) | 470 (336; 563)A
Klarskov, 1986 ^671^ | Surgery: Burch colposuspension when patients had anterior suspension defect. Vaginal repair when patients had posterior bladder descent | Pelvic floor training program 5 times in weekly lessons guided by trained physiotherapists | Self reported improvement in urinary incontinence | 7 | 14 | 26.9 | 58.3 | 0.5 (0.2; 0.9) | 3 (2; 32) | 314 (31; 452)A
N = 40
Berglund, 1996 ^649^ | Retropubic urethrocystopexy | Pubococcygeal repair | Improved stress urinary incontinence | 8 | 3 | 26.7 | 20.0 | 1.3 (0.4; 4.3)
N = 45
Kitchener, 2006 ^655^ | Laparoscopic colposuspension | Open abdominal retropubic colposuspension | Improvement in stress urinary incontinence with <1 leak/month | 39 | 48 | 26.5 | 33.3 | 0.8 (0.6; 1.1)
N = 291
Persson, 2000 ^666^ | Laparoscopic Burch colposuspension using one double-bite of polytetrafluoroet hylene sutures placed on each side of the urethra under transperitoneal video laparoscopy | Laparoscopic Burch colposuspension using two single-bite sutures of polytetrafluoroethylene sutures placed on each side of the urethra under transperitoneal video laparoscopy | Improved pad test | 20 | 9 | 25.6 | 10.8 | 2.4 (1.1; 4.9) | 7 (63; 2) | 148 (16; 420)E
N = 161
Lalos, 1993 ^650^ | Retropubic urethrocystopexy | Pubococcygeal repair | Improved stress urinary incontinence | 5 | 3 | 22.7 | 21.4 | 1.1 (0.3; 3.8)
N = 36
El-Barky, 2005 ^645^ | Burch colposuspension | Tension-free vaginal tape procedure | Improved stress urinary incontinence | 4 | 5 | 16.0 | 20.0 | 0.8 (0.2; 2.6)
N = 50
Wang, 2003 ^646^ | Modified Burch colposuspension | Tension-free vaginal taping | Objective improvement as decrease un urine loss during pad test by >50% from baseline | 5 | 4 | 10.2 | 8.2 | 1.3 (0.4; 4.4)
N = 98
Colombo, 1994 ^662^ | Burch colposuspension | Modified Marshall-Marchetti-Krantz urethropexy | Subjective improvement as clinical score of incontinence decreased; from 8 to ≤4 or from 4 to ≤2. | 3 | 6 | 7.5 | 15.0 | 0.5 (0.1; 1.9)
N = 80
Liapis, 2002 ^642^ | Burch colposuspension | Tension-free vaginal tape procedure | Improvement as reduction of urine loss to less than 50% of urine loss at baseline during 1 hour pad test | 2 | 3 | 6.0 | 7.0 | 0.7 (0.1; 3.9)
N = 71

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F133 Effects of surgical interventions on risk and progression of urinary incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcomes | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sand, 2000 ^638^ | Burch procedures with four 2-0 polytetrafluoroet hylene sutures and tension placed on the periurethral sutures (modified Tanagho method) | Suburethral sling with continuous polytetraflouroeth ylene strip from rectus fascia into Retropubic space and beneath urethra at urethrovesical junction level | De novo Detrusor instability | 1 | 4 | 5.3 | 23.5 | 0.2 (0.0; 1.8)
N = 36
Culligan, 2003 ^640^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension | De novo Detrusor instability | 1 | 4 | 5.3 | 23.5 | 0.2 (0.0; 1.8)
N = 36
Laurikainen, 2007 ^629^ | Retropubic tension-free vaginal polypropylene tape procedure by Ulmsten | Transobturator tension-free vaginal polypropylene tape procedure by de Leval | De novo urge symptoms | 3 | 3 | 2.2 | 2.3 | 1.0 (0.2; 4.7)
N = 273
Paraiso, 2004 ^643^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Detrusor over activity | 2 | 6 | 5.6 | 16.7 | 0.3 (0.1; 1.5)
N = 72
Bump, 1996 ^635^ | Needle colposuspension | Bladder neck endopelvic fascia plication | Emptying phase dysfunction | 5 | 7 | 31.0 | 43.0 | 0.7 (0.3; 1.8)
N = 32
Demirci, 2001 ^639^ | Burch colposuspension (Tanagho); 9 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy. | McGuire's free-rectus Fascial sling from inferior leaf of rectus fascia (length 5 to 6cm, 2cm in center diameter and 1.5cm at either end; 8 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy. | Incidence of Detrusor instability | 1 | 1 | 4.3 | 4.3 | 1.0 (0.1; 15.0)
N = 46
Costantini, 2007 ^652^ | Sacropexy combined with a Burch colposuspension | Colposacropexy, no prophylactic colposuspension | Incidence of mixed urinary Incontinence | 3 | 2 | 8.8 | 6.3 | 1.4 (0.3; 7.9)
N = 66 | | | Incidence of stress urinary Incontinence | 9 | 1 | 26.5 | 3.1 | 8.5 (1.1; 63.1) | 4 (2; 235) | 233 (4; 1,942)E
Gilja, 1998 ^648^ | Burch retropubic urethropexy | Modified bladder neck suspension by Raz | Incidence of urge urinary incontinence | 1 | 3 | 1.8 | 6.5 | 0.3 (0.0; 2.5)
N = 204 | Transvaginal Burch procedure | Modified bladder neck suspension by Raz | Incidence of urge urinary incontinence | 2 | 3 | 4.5 | 6.5 | 0.7 (0.1; 4.0)
Costantini, 2007 ^652^ | Sacropexy combined with a Burch colposuspension | Colposacropexy, no prophylactic colposuspension | Incidence of urinary Incontinence | 12 | 3 | 35.3 | 9.4 | 3.8 (1.2; 12.1) | 4 (1;63) | 259 (16; 1,043)E
N = 66 | | | Incidence of urinary Incontinence in those with MUCP<35c m/H20 | 5 | 2 | 14.7 | 6.3 | 2.4 (0.5; 11.3)
| | | Incidence of urinary Incontinence in those with MUCP>35c m/H20 | 6 | 1 | 17.6 | 3.1 | 5.6 (0.7; 44.4)
El-Barky, 2005 ^645^ | Burch colposuspension | Tension-free vaginal tape procedure | Incidence of urinary urgency | 3 | 2 | 12.0 | 8.0 | 1.5 (0.3; 8.2)
N = 50
German, 1994 ^658^ | Modified needle suspension procedure | Vagina/obturator shelf procedure | Incidence of urinary urgency | 2 | 1 | 7.7 | 4.2 | 1.8 (0.2; 19.1)
N = 50
Ankardal, 2005 ^668^ | Open Burch colposuspension using sutures | Laparoscopic colposuspension using sutures | Leakage <5g at stress test | 55 | 43 | 69.6 | 81.1 | 0.9 (0.7; 1.0)
N = 211 | Open Burch colposuspension using sutures | Laparoscopic colposuspension using mesh and staples | Leakage <5g at stress test | 55 | 44 | 69.6 | 83.0 | 0.8 (0.7; 1.0)
| Open Burch colposuspension using sutures | Laparoscopic colposuspension using sutures | Leakage<8g/ 24 hour at 48-hour pad test | 56 | 39 | 70.9 | 73.6 | 1.0 (0.8; 1.2)
| Open Burch colposuspension using sutures | Laparoscopic colposuspension using mesh and staples | Leakage<8g /24 hour at 48-hour pad test | 56 | 51 | 70.9 | 96.2 | 0.7 (0.6; 0.9) | 4 (3; 7) | 253 (138;353)A
Ankardal, 2004 ^669^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using mesh and staples | Leakage<8g /24 hour at 48-hour pad test | 84 | 71 | 70.0 | 59.2 | 1.2 (1.0; 1.4)
N = 240
Colombo, 1996 ^633^ | Cystopexy alone | Cystopexy with posterior pubourethral ligaments plication | negative cotton swab test 6 months after surgery | 23 | 40 | 42.6 | 75.5 | 0.6 (0.4; 0.8) | 3 (2; 7) | 329 (153;453)A
N = 107
Kammerer-Doak, 1999 ^664^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Pad weight <1g | 15 | 6 | 78.9 | 37.5 | 2.1 (1.1; 4.1) | 2 (36; 1) | 414 (27; 1,174)E
N = 35
Culligan, 2003 ^640^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension. | Positive pad test | 1 | 0 | 7.6 | 0.1 | 2.7 (0.1; 62.2)
N = 36
Ustun, 2003 ^644^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Positive Q-Tip test | 0 | 2 | 0.1 | 8.6 | 0.2 (0.0; 4.0)
N = 46
Bergman, 1989 ^665^ | Burch urethropexy | Modified Pereyra needle urethropexy | Positive Q-tip test (>35 degrees) | 1 | 18 | 2.6 | 52.9 | 0.0 (0.0; 0.4) | 2 (2; 3) | 503 (343;526)A
N = 127 | Burch urethropexy | Anterior colporrhaphy with Kelly plication | Positive Q-tip test (>35 degrees) | 1 | 27 | 2.6 | 77.1 | 0.0 (0.0; 0.2) | 1 (1; 2) | 745 (588;768)A
Culligan, 2003 ^640^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension. | Positive stress test | 3 | 0 | 15.4 | 0.1 | 6.3 (0.3; 113.8)
N = 36
Brubaker, 2006 ^634^ | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Positive Stress testing (bladder volume at maximum cystometric capacity of 300ml) | 7 | 14 | 4.7 | 8.6 | 0.5 (0.2; 1.3)
N = 322
Colombo, 1997 ^636^ | Posterior pubourethral ligament placation | Pereyra suspension | Self reported stress urinary incontinence | 20 | 21 | 36.4 | 38.9 | 0.9 (0.6; 1.5)
N = 109
Brubaker, 2006 ^634^ | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Self reported symptoms of stress incontinence 3 months after surgery | 29 | 60 | 19.0 | 39.7 | 0.5 (0.3; 0.7) | 5 (4; 10) | 207 (100; 260)A
N = 322 | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Self reported urge urinary incontinence 3 months after surgery | 10 | 18 | 6.8 | 11.9 | 0.6 (0.3; 1.2)
| Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Self reported urinary urgency 3 months after surgery | 9 | 14 | 5.9 | 9.2 | 0.7 (0.3; 1.5)
| Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Stress incontinence 3 months after surgery | 35 | 67 | 23.8 | 44.1 | 0.5 (0.4; 0.8) | 5 (4; 10) | 203 (99; 270)A
Osman, 2003 ^651^ | Burch retropubic suspension or Pubovaginal sling | Oxybutynin hydrochloride 5mg 3 times/day | Stress urinary incontinence | 1 | 12 | 2.0 | 48.0 | 0.0 (0.0; 0.3) | 2 (2; 3) | 460 (335; 477)A
N = 75
Colombo, 1996 ^633^ | Cystopexy alone | Cystopexy with posterior pubourethral ligaments plication | Stress urinary incontinence 1 year after surgery | 4 | 4 | 7.4 | 7.5 | 1.0 (0.3; 3.7)
N = 107 | Cystopexy alone | Cystopexy with posterior pubourethral ligaments plication | Stress urinary incontinence 6 months after surgery | 4 | 3 | 7.4 | 5.7 | 1.3 (0.3; 5.6)
Brubaker, 2006 ^634^ | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Urge outcome 3 months after surgery | 50 | 58 | 32.7 | 38.4 | 0.9 (0.7; 1.2)
N = 322
Paraiso, 2004 ^643^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Urge urinary incontinence | 11 | 5 | 30.0 | 15.0 | 2.2 (0.9; 5.7)
N = 72
Osman, 2003 ^651^ | Burch retropubic suspension or Pubovaginal sling | Oxybutynin hydrochloride 5mg 3 times/day | Urge urinary incontinence | 4 | 0 | 8.0 | 0.0 | 4.6 (0.3; 82.0)
N = 75
Kammerer-Doak, 1999 ^664^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Urinary urgency several times/week | 4 | 8 | 21.1 | 50.0 | 0.4 (0.2; 1.1)
N = 35
Paraiso, 2004 ^643^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Urodynamic stress incontinence | 6 | 1 | 16.7 | 2.8 | 6.0 (0.8; 47.4)
N = 72 | | | Using pads for urinary incontinence | 11 | 10 | 30.0 | 29.0 | 1.1 (0.5; 2.3)
Brubaker, 2006 ^634^ | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Bothersome stress incontinence 3 months after surgery | 9 | 37 | 6.1 | 24.5 | 0.3 (0.1; 0.5) | 5 (5; 8) | 184 (120; 214)A
N = 322
Albo, 2007 ^672^ | Burch colposuspension | Pubovaginal sling, using autologous rectus fascia | Voiding dysfunction | 7 | 46 | 2.0 | 14.0 | 0.2 (0.1; 0.3) | 8 (8; 11) | 120 (94; 130)A
N = 655 | | | Incidence of urge incontinence | 11 | 11 | 3.3 | 3.4 | 1.0 (0.4; 2.3)
| | | Postoperative urge incontinence that needed treatment | 65 | 87 | 19.8 | 26.7 | 0.7 (0.6; 1.0)
| | | Persistent urge incontinence | 59 | 79 | 17.9 | 24.2 | 0.7 (0.5; 1.0)
| | | Treatment failure | 179 | 151 | 54.3 | 46.3 | 1.2 (1.0; 1.4) | 13 (459; 6) | 79 (2; 169)E
| | | Positive stress test | 74 | 34 | 22.5 | 10.6 | 2.2 (1.5; 3.1) | 8 (20; 4) | 119 (51; 226)E
Carey, 2006 ^673^ | Laparoscopic Burch colposuspension | Open Burch colposuspension | Self reported urinary stress incontinence | 20 | 23 | 19.23 | 23.96 | 0.80 (0.47; 1.37)
N = 200 | | | Detrusor overactivity | 13 | 10 | 12.50 | 10.42 | 1.20 (0.55; 2.61)
6 months | | | Self reported urinary stress incontinence and/or Detrusor overactivity | 29 | 30 | 27.88 | 31.25 | 0.89 (0.58; 1.37)
| | | Stress incontinence Occasionally | 18 | 24 | 17.31 | 25.00 | 0.69 (0.40; 1.19)
| | | Stress incontinence Frequently | 9 | 5 | 8.65 | 5.21 | 1.66 (0.58; 4.78)
| | | Urinary urgency: Occasionally | 44 | 30 | 42.31 | 31.25 | 1.35 (0.93; 1.96)
| | | Urinary urgency: Frequently | 9 | 17 | 8.65 | 17.71 | 0.49 (0.23; 1.04)
| | | Urge incontinence: Occasionally | 334 | 29 | 32.69 | 30.21 | 1.08 (0.72; 1.63)
| | | Urge incontinence Frequently | 9 | 13 | 8.65 | 13.54 | 0.64 (0.29; 1.43)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E- excessive events

Table F134 Effect of surgical interventions on self reported severity of urinary incontinence in females

Author | Active | Control | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95%CI) | Change % From Control (95%CI)
Kammerer-Doak, 1999 ^664^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Self assessment score (1 =dry, 10 = severe leakage) | 1.0 ± 4.7 | 5.0 ± 2.7 | -1.0 (-1.7; -0.3) | -20.6 (-34.8; -6.4)
N = 35
Brubaker, 2006 ^634^ | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Medical, Epidemiological, and Social Aspects of Aging score for stress incontinence (0-never to 3-often for 9 questions) | 13.3 ± 19.0 | 23.3 ± 24.7 | -0.5 (-0.7; -0.2) | -1.9 (-2.9; -1.0)
N = 322
Klarskov, 1986 ^671^ | Surgery: Burch colposuspension when patients had anterior suspension defect. Vaginal repair when patients had posterior bladder descent | Pelvic floor training program 5 times in weekly lessons guided by trained physiotherapists | Number of incontinence episodes/3 days | 0.0 9± .3 | 2.0 ± 12.0 | -0.2 (-0.7; 0.4) | -9.4 (-37.2; 18.5)
N = 40
Kammerer-Doak, 1999 ^664^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Overall quality of life according to the Incontinence Impact Questionnaire | 0.3 ± 0.2 | 0.9 ±0.0 | -4.3 (-5.5; -3.0) | -469.7 (-604.6; - 334.9)
N = 35 | | | Incontinence episodes/week | 0.0 ± 4.0 | 4.0 ± 1.3 | -1.3 (-2.0; -0.6) | -32.4 (-50.8; -14.0)
| | | Pads/week | 0.0 ± 2.7 | 3.0 ± 0.7 | -1.5 (-2.2; -0.7) | -49.5 (-74.7; -24.3)
Brubaker, 2006 ^634^ | Sacrocolpopexy with Burch colposuspension | Sacrocolpopexy alone | Medical, Epidemiological, and Social Aspects of Aging score for urinary urge (0-never to 3-often for 9 questions) | 11.8 ± 14.0 | 16.8 ± 18.8 | -0.3 (-0.5; -0.1) | -1.8 (-3.1; -0.5)
N = 322
Paraiso, 2004 ^643^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Questionnaire with scores range from 0 to 400, with larger scores indicating greater adverse impact on quality of life. | 38.0 ± 51.0 | 49.0 ± 38.0 | -0.2 (-0.7; 0.2) | -0.5 (-1.4; 0.4)
N = 72 | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Urogenital Distress Inventory scores from 0 to 300, larger scores indicating greater distress | 4.0 ± 2.0 | 6.0 ± 2.0 | -1.0 (-1.5; -0.5) | -16.7 (-24.8; -8.5)
| Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Incontinence episodes/week | 0.4 ± 1.6 | 1.8 ± 5.1 | -0.4 (-0.8; 0.1) | -20.6 (-46.5; 5.3)
Kitchener, 2006 ^655^ | Laparoscopic colposuspension | Open abdominal retropubic colposuspension | Physical subscale in quality of life (SF-36 scores) | 79.3 ± 27.6 | 77.6 ± 27.7 | 0.1 (-0.2; 0.3) | 0.1 (-0.2; 0.4)
N = 291
Ankardal, 2004 ^669^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | Quality of life: working ability (100 = maximum bother) | 0.0 ± 0.0 | 0.0 ± 8.7
N = 240
Laurikainen, 2007 ^629^ | Retropubic tension-free vaginal polypropylene tape procedure by Ulmsten | Transobturator tension-free vaginal polypropylene tape procedure by de Leval | Urogenital Distress Inventory-Short Form | 7.0 ± 2.0 | 7.0 ± 1.0 | 0.0 (-0.2; 0.2) | 0.0 (-3.4; 3.4)
N = 273 | | | Incontinence Impact Questionnaire-Short Form | 8.0 ± 2.0 | 7.0 ± 2.0 | 0.5 (0.3; 0.7) | 7.1 (3.7; 10.6)
| | | Visual analog scale | 7.0 ± 14.0 | 6.0 ± 1.0 | 0.1 (-0.1; 0.3) | 1.7 (-2.3; 5.7)
| | | Detrusor Instability Score | 2.0 ± 2.0 | 2.0 ± 2.0 | 0.0 (-0.2; 0.2) | 0.0 (-12.0; 12.0)
| | | Urinary Incontinence Severity Score | 0.7 ± 1.6 | 0.4 ± 1.0 | 0.2 (0.0; 0.5) | 56.0 (-4.0; 116.1)
Ankardal, ^669^ | Open Burch colposuspension using sutures | Laparoscopic transperitoneal colposuspension using polypropylene mesh and staples | Quality of life: social life (100 = maximum bother) | 0.0 ± 0.0 | 0.0 ± 13.3
N = 240 | | | Quality of life: physical activity (100 = maximum bother) | 0.0 ± 2.7 | 1.0 ± 30.7 | 0.0 (-0.3; 0.2) | -4.6 (-29.9; 20.7)
Laurikainen, ^629^ | Retropubic tension-free vaginal polypropylene tape procedure by Ulmsten | Transobturator tension-free vaginal polypropylene tape procedure by de Leval | Euro Quality-of-Life Five Dimensions Index | 0.9 ± 0.1 | 0.9 ± 0.1 | -0.1 (-0.4; 0.1) | -12.8 (-38.4; 12.8)
N = 273
Roovers, 2004 ^637^ | Vaginal hysterectomy (combined with anterior and/or posterior colporraphy) | Abdominal sacrocolpopexy (with preservation of the uterus) on Urogenital function | Urogenital distress inventory scores for overactive bladder | 9.4 ± 2.2 | 18.1 ± 3.5 | -3.0 (-3.6; -2.3) | -16.4 (-19.9; -12.9)
N = 82 | | | Urogenital distress inventory scores for urinary incontinence | 7.2 ± 2.1 | 13.2 ± 3.5 | -2.1 (-2.6; -1.5) | -15.7 (-19.8; -11.7)
Carey, 2006 ^673^ | Laparoscopic Burch colposuspension | Open Burch colposuspension | General health | 2.60 ± 1.02 | 2.22 ± 1.06 | 0.37 (0.09; 0.65) | 16.47 (3.87; 29.07)
N = 200 | | | SF-36 Physical Component Summary | 49.54 ± 10.41 | 49.14 ± 11.21 | 0.04 (-0.24; 0.31) | 0.08 (-0.49; 0.64)
| | | SF-36 Mental Component Summary | 42.70 ± 13.03 | 48.31 ± 10.01 | -0.48 (-0.76; -0.20) | -0.99 (-1.58; -0.41)
| | | the Short Urinary Distress Inventory | 23.92 ± 17.90 | 21.56 ± 16.92 | 0.14 (-0.14; 0.41) | 0.63 (-0.66; 1.92)
| | | Short Incontinence Impact Questionnaire | 31.40 ± 23.83 | 26.87 ± 29.36 | 0.17 (-0.11; 0.45) | 0.63 (-0.40; )1.67

Bold- significant differences in outcomes at 95% confidence level

Table F135 Effect of surgical interventions on progression of urinary incontinence in females (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean difference (95%CI) | Change % From Control (95%CI)
Demirci, 2001 ^639^ | Burch colposuspension (Tanagho), 9 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy. | McGuire's free-rectus Fascial sling from inferior leaf of rectus fascia (length 5 to 6cm, 2cm in center diameter and 1.5cm at either end; 8 patients had abdominal hysterectomy with or without bilateral salpingo-oopherectomy. | Bladder neck position, (mm) | 25.0 ± 4.6 | 24.4 ± 3.7 | 0.2 (-0.4; 0.7) | 0.6 (-1.7; 3.0)
N = 46
Culligan, 2003 ^640^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension. | Post void residual volume (ml) | 51.8 ± 89.7 | 31.1 ± 27.0 | 0.3 (-0.4; 1.0) | 1.0 (-1.1; 3.1)
N = 36 | | | Average flow rate during void (ml/second) | 4.7 ± 3.0 | 4.8 ± 2.8 | 0.0 (-0.7; 0.6) | -0.7 (-14.3; 12.9)
| | | Maximum cystometric capacity (ml) | 398.0 ± 76.8 | 444.0 ± 95.9 | -0.5 (-1.2; 0.1) | -0.1 (-0.3; 0.0)
| | | Functional urethral length (mm) | 25.7 ± 10.0 | 27.2 ± 7.3 | -0.2 (-0.8; 0.5) | -0.6 (-3.0; 1.8)
| | | Pressure transmission ratio | 1.1 ± 0.2 | 1.5 ± 0.4 | -1.4 (-2.1; -0.7) | -91.3 (-139.0; -43.6)
| | | Maximum urethral closure pressure (cm/H2O) | 16.4 ± 8.2 | 39.8 ± 23.0 | -1.4 (-2.1; -0.7) | -3.5 (-5.3; -1.6)
Ustun, 2003 ^644^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Bladder capacity, (ml) | 489.4 ± 1,16.0 | 484. ± 140.1 | 0.0 (-0.5; 0.6) | 0.0 (-0.1; 0.1)
N = 46
Lalos, 1993 ^650^ | Retropubic urethrocystopexy | Pubococcygeal repair | Maximal flow rate | 19.5 ± 19.7 | 18.0 ± 10.7 | 0.1 (-0.6; 0.8) | 0.5 (-3.2; 4.2)
N = 36 | | | Bladder volume, (ml) | 567.5 ± 178.3 | 662.5 ± 171.7 | -0.5 (-1.2; 0.1) | -0.1 (-0.2; 0.0)
Colombo, 1996 ^647^ | Burch colposuspension with placement of two couples of permanent polybutylate-coated polyester sutures | Abdominal paravaginal defect repair with 5–7 pairs of permanent braided silicone-coated polyester suture. | Maximum straining angle at cotton swab test | 17.4 ± 5.8 | 31.4 ± 11.2 | -1.6 (-2.3; -0.8) | -5.0 (-7.4; -2.6)
N = 36
Wang, 2003 ^646^ | Modified Burch colposuspension | Tension-free vaginal taping | PdetQmax (cm/H2O) | 13.0 ± 18.7 | 17.0 ± 38.7 | -0.1 (-0.5; 0.3) | -0.8 (-3.1; 1.6)
N = 98 | | | Pdetmax (cm/H2O) | 30.0 ± 58.7 | 28.0 ± 45.3 | 0.0 (-0.4; 0.4) | 0.1 (-1.3; 1.6)
| | | Residual urine (ml) | 20.0 ± 320.0 | 20.0 ± 53.3 | 0.0 (-0.4; 0.4) | 0.0 (-2.0; 2.0)
Ustun, 2003 ^644^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | First desire to mixture (ml) | 158.2 ± 112.5 | 161.7 ± 58.7 | 0.0 (-0.6; 0.5 0 | 0.0 (-0.4; 0.3)
N = 46
Wang, 2003 ^646^ | Modified Burch colposuspension | Tension-free vaginal taping | Volume voided (ml) | 271.0 ± 283.3 | 255.0 ± 342.7 | 0.1 (-0.3; 0.4) | 0.0 (-0.1; 0.2)
N = 98
Sand, 2000 ^638^ | Burch procedures with four 2-0 polytetrafluoroethylene sutures and tension placed on the periurethral sutures (modified Tanagho method) | Suburethral sling with continuous polytetraflouroethylene strip from rectus fascia into Retropubic space and beneath urethra at urethrovesical junction level | Pressure transmission ratio | 1.1 ± 0.2 | 1.5 ± 0.4 | -1.4 (-2.1; -0.7) | -91.3 (-139.0; -43.6)
N = 36
Ustun, 2003 ^644^ | Laparoscopic Burch colposuspension | Tension-free vaginal tape procedure | Maximum flow rate (ml/second) | 42.9 ± 8.1 | 35.9 ± 9.3 | 0.8 (0.2; 1.4) | 2.2 (0.6; 3.9)
N = 46 | | | Maximum Detrusor activity (cm/H20) | 12.0 ± 6.2 | 9.2 ± 6.4 | 0.4 (-0.1; 1.0) | 4.9 (-1.5; 11.3)
| | | Leak point pressure (cm/H20) | 68.3 ± 22.3 | 104.7 ± 9.1 | -2.1 (-2.9; -1.4) | -2.0 (-2.7; -1.3)
Liapis, 2002 ^642^ | Burch colposuspension | Tension-free vaginal tape procedure | Peak flow rate (ml/second) | 25.8 ± 9.5 | 26.7 ± 9.0 | -0.1 (-0.6; 0.4) | -0.4 (-2.1; 1.4)
N = 71
Culligan, 2003 ^640^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension. | Average flow rate during void (ml/second) | | | 0.58 (-2.5; 4.4)
N = 36
Wang, 2003 ^646^ | Modified Burch colposuspension | Tension-free vaginal taping | FreeQmax (ml/second) | 19.1 ± 16.2 | 19.0 ± 19.2 | 0.0 (-0.4; 0.4) | 0.0 (-2.1; 2.1)
N = 98
Bump, 1996 ^635^ | Needle colposuspension | Bladder neck endopelvic fascia plication | Mean pressure transmission %6 weeks after operation | 120.0 ± 22.0 | 94.0 ± 14.0 | 1.4 (0.6; 2.2) | 1.5 (0.7; 2.3)
N = 32 | | | Mean closure pressure (cm/H20) 6 weeks after operation | 16.0 ± 4.0 | 21.0 ± 12.0 | -0.6 (-1.3; 0.1) | -2.7 (-6.0; 0.7)
| | | Maximum closure pressure (cm/H20) 6 weeks after operation | 35.0 ± 21.0 | 27.0 ± 10.0 | 0.5 (-0.2; 1.2) | 1.8 (-0.8; 4.4)
| | | Functional length (mm) 6 weeks after operation | 35.0 ± 12.0 | 25.0 ± 6.0 | 1.1 (0.3; 1.8) | 4.2 (1.2; 7.2)
Colombo, 1996 ^633^ | Cystopexy alone | Cystopexy with posterior pubourethral ligaments plication | Maximum urethral closure pressure (cm/H2O) 6 months after surgery | 72.8 ± 30.0 | 75.6 ± 36.4 | -0.1 (-0.5; 0.3) | -0.1 (-0.6; 0.4)
N = 107
Bump, 1996 ^635^ | Needle colposuspension | Bladder neck endopelvic fascia plication | Maximum closure pressure (cm/H20) 6 months after operation | 47.0 ± 29.0 | 44.0 ± 23.0 | 0.1 (-0.6; 0.8) | 0.3 (-1.3; 1.8)
N = 32 | Needle colposuspension | Bladder neck endopelvic fascia plication | Mean closure pressure (cm/H20) 6 months after operation | 25.0 ± 12.0 | 26.0 ± 12.0 | -0.1 (-0.8; 0.6) | -0.3 (-3.0; 2.3)
Colombo, 1996 ^633^ | Cystopexy alone | Cystopexy with posterior pubourethral ligaments plication | Urethral functional length (mm) 6 months after surgery | 25.7 ± 5.4 | 28.1 ± 5.3 | -0.4 (-0.8; -0.1) | -1.6 (-3.0; -0.2)
N = 107
Sand, 2000 ^638^ | Burch procedures with four 2-0 polytetrafluoroethylene sutures and tension placed on the periurethral sutures (modified Tanagho method) | Suburethral sling with continuous polytetraflouroethylene strip from rectus fascia into Retropubic space and beneath urethra at urethrovesical junction level | Functional urethral length (mm) | 25.7 ± 10.0 | 27.2 ± 7.3 | -0.2 (-0.8; 0.5) | -0.6 (-3.0; 1.8)
N = 36 | | | Maximum voiding Detrusor pressure (cm/H2O) | 21.3 ±8.0 | 28.8 ± 12.3 | -0.7 (-1.4; -0.1) | -2.5 (-4.9; -0.2)
| | | Average flow rate during void (ml/second) | 4.7 ± 3.0 | 4.8 ± 2.8 | 0.0 (-0.7; 0.6) | -0.7 (-14.3; 12.9)
| | | Maximum flow rate during void (ml/second) | 10.6 ± 5.3 | 13.5 ± 6.6 | -0.5 (-1.2; 0.2) | -3.6 (-8.5; 1.3)
| | | Post void residual volume (ml) | 51.8 ± 89.7 | 31.1 ± 27.0 | 0.3 (-0.4; 1.0) | 1.0 (-1.1; 3.1)
Bump, 1996 ^635^ | Needle colposuspension | Bladder neck endopelvic fascia plication | Functional length (mm) 6 months after operation | 25.0 ± 7.0 | 25.0 ± 7.0 | 0.0 (-0.7; 0.7) | 0.0 (-2.8; 2.8)
N = 32
Sand, 2000 ^638^ | Burch procedures with four 2-0 polytetrafluoroethylene sutures and tension placed on the periurethral sutures (modified Tanagho method) | Suburethral sling with continuous polytetraflouroethylene strip from rectus fascia into Retropubic space and beneath urethra at urethrovesical junction level | Maximum urethral closure pressure (cm/H2O) | 16.4 ± 8.2 | 39.8 ± 23.0 | -1.4 (-2.1; -0.7) | -3.5 (-5.3; -1.6)
N = 36
Lalos, 1993 ^650^ | Retropubic urethrocystopexy | Pubococcygeal repair | Urethral length, (mm) | 25.0 ± 8.7 | 26.0 ± 6.7 | -0.1 (-0.8; 0.5) | -0.5 (-3.1; 2.1)
N = 36
Colombo, 1997 ^636^ | Posterior pubourethral ligament placation | Pereyra suspension | Maximum urethral closure pressure (cm/H2O) | 56.2 ± 23.5 | 70.6 ± 35.9 | -0.5 (-0.9; -0.1) | -0.7 (-1.2; -0.1)
N = 109
Culligan, 2003 ^640^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension | Maximum voiding Detrusor pressure (cm/H2O) | 21.3 ± 8.0 | 28.8 ± 12.3 | -0.7 (-1.4; -0.1) | -2.5 (-4.9; -0.2)
N = 36
Colombo, 1997 ^636^ | Posterior pubourethral ligament placation | Pereyra suspension | Urethral functional length (mm) | 26.8 ± 4.2 | 25.5 ± 4.9 | 0.3 (-0.1; 0.7) | 1.1 (-0.4; 2.6)
N = 109
Bump, 1996 ^635^ | needle colposuspension | Bladder neck endopelvic fascia plication | Mean pressure transmission % 6 months after operation | 125.0 ± 55.0 | 104.0 ± 30.0 | 0.5 (-0.2; 1.2) | 0.5 (-0.2; 1.1)
N = 32
Su, 1997 ^657^ | Laparoscopic colposuspension | Open Burch colposuspension | Bladder neck position, rest | 0.8 ± 0.4 | 0.9 ± 0.5 | -0.3 (-0.7; 0.1) | -34.2 (-80.9; 12.5)
N = 92
Kammerer-Doak, 1999 ^664^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Proximal transmission ratio | 102.4 ± 15.0 | 77.2 ± 23.0 | 1.3 (0.6; 2.1) | 1.7 (0.8; 2.7)
N = 35
Cheon, 2003 ^656^ | Laparoscopic colposuspension | Burch open colposuspension | Urine loss in pad test, g | 3.6 ± 11.1 | 4.4 ± 20.3 | 0.0 (-0.5; 0.4) | -1.1 (-10.5; 8.3)
N = 90
Bergman, 1995 ^663^ | Burch urethropexy | Modified Pereyra needle urethropexy | Urethral functional test | 2.3 ± 1.3 | 2.9 ± 1.3 | -0.5 (-0.9; 0.0) | -15.9 (-32.0; 0.1)
N = 127 | | | Urethral closure pressure | 25.0 ± 10.0 | 36.0 ± 9.0 | -1.2 (-1.7; -0.7) | -3.2 (-4.6; -1.8)
Su, 1997 ^657^ | Laparoscopic colposuspension | Open Burch colposuspension | Volume at first desire to void, ml | 175.9 ± 65.3 | 164.4 ± 26.0 | 0.2 (-0.2; 0.6) | 0.1 (-0.1; 0.4)
N = 92 | | | Maximum cystometric capacity, ml | 344.9 ± 52.7 | 335.3 ± 40.1 | 0.2 (-0.2; 0.6) | 0.1 (-0.1; 0.2)
| | | Maximal urethral pressure (cm/H20) | 78.3 ± 16.9 | 82.5 ± 19.8 | -0.2 (-0.6; 0.2) | -0.3 (-0.8; 0.2)
| | | Urethral closure pressure at rest (cm/H20) | 67.1 ± 16.6 | 71.2 ± 18.1 | -0.2 (-0.6; 0.2) | -0.3 (-0.9; 0.2)
Bergman, 1995 ^663^ | Burch urethropexy | Modified Pereyra needle urethropexy | Pressure transmission ratio | 89.0 ± 6.0 | 89.0 ± 10.0 | 0.0 (-0.5; 0.5) | 0.0 (-0.5; 0.5)
N = 127
Su, 1997 ^657^ | Laparoscopic colposuspension | Open Burch colposuspension | Minimal urethral resistance | 0.2 ± 0.2 | 0.3 ± 0.3 | -0.3 (-0.7; 0.1) | -99.9 (-223.8; 24.1)
N = 92
Kammerer-Doak, 1999 ^664^ | Burch retropubic urethropexy | Modified anterior colporrhaphy | Midurethral pressure transmission ratio | 94.3 ± 11.0 | 75.7 ± 13.0 | 1.6 (0.8; 2.3) | 2.1 (1.0; 3.1)
N = 35
Bergman, 1995 ^663^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | Urethral functional test | 2.3 ± 1.3 | 3.1 ± 1.3 | -0.6 (-1.1; -0.1) | -19.9 (-35.0; -4.7)
N = 127
Su, 1997 ^657^ | Laparoscopic colposuspension | Open Burch colposuspension | Urine loss in 1 hour pad test | 1.6 ± 4.9 | 2.9 ± 8.4 | -0.2 (-0.6; 0.2) | -6.4 (-20.4; 7.5)
N = 92 | | | Bladder neck position, stress | 0.2 ± 0.5 | 0.6 ± 0.6 | -0.7 (-1.2; -0.3) | -132.6 (-209.4; -55.8)
Bergman, 1995 ^663^ | Burch urethropexy | Anterior colporrhaphy with Kelly plication | Urethral closure pressure | 25.0 ± 10.0 | 44.0 ± 22.0 | -1.1 (-1.6; -0.6) | -2.6 (-3.7; -1.4)
N = 127 | | | Pressure transmission ratio | 89.0 ± 6.0 | 74.0 ± 14.0 | 1.4 (0.9; 1.9) | 1.9 (1.2; 2.6)
Colombo, 1994 ^662^ | Burch colposuspension | Modified Marshall-Marchetti-Krantz urethropexy | Urethral resistance | 0.6 ± 0.1 | 0.3 ± 0.1 | 3.0 (2.3; 3.6) | 1,017.8 (797.9; 1,237.7)
N = 80 | | | Detrusor pressure at peak flow, cm/H20 | 28.7 ± 12.6 | 21.4 ± 11.8 | 0.6 (0.1; 1.0) | 2.8 (0.7; 4.9)
| | | Mean flow, ml/second | 8.8 ± 4.8 | 6.7 ± 4.2 | 0.5 (0.0; 0.9) | 6.9 (0.3; 13.6)
| | | Peak flow. Ml/second | 13.0 ± 5.6 | 16.5 ± 7.7 | -0.5 (-1.0; -0.1) | -3.2 (-5.9; -0.4)
Quadri, 1999 ^661^ | Burch colposuspensions | Marshall-Marchetti-Krantz urethropexy with video urethroscopic control | Urethral functional length (mm) in cured | 21.5 ± 4.2 | 23.6 ± 7.5 | -0.3 (-1.1; 0.4) | -1.5 (-4.5; 1.6)
N = 30 | | | Maximum urethral closure pressure (cm/H2O) in cured | 20.3 ± 6.3 | 23.9 ± 12.1 | -0.4 (-1.1; 0.3) | -1.6 (-4.6; 1.5)
Laurikainen, 2007 ^629^ | Retropubic tension-free vaginal polypropylene tape procedure by Ulmsten | Transobturator tension-free vaginal polypropylene tape procedure by de Leval | Post void residual urine volume | 28.0 ± 49.0 | 43.0 ± 78.0 | -0.2 (-0.5; 0.0) | -0.5 (-1.1; 0.0)
N = 273
Culligan, 2003 ^640^ | Burch colposuspension (Tanagho) | Suburethral sling (Horbach) with polytetrafluororthylene strip from rectum fascia beneath urethra under minimal tension. | Maximum flow rate during void (ml/second) | 10.6 ± 5.3 | 13.5 ± 6.6 | -0.5 (-1.2; 0.2) | -3.6 (-8.5; 1.3)
N = 36
Su, 1997 ^657^ | Laparoscopic colposuspension | Open Burch colposuspension | Transmission ratio, Q4 | 0.3 ± 0.2 | 0.2 ± 0.2 | 0.4 (-0.1; 0.8) | 149.1 (-21.2; 319.3)
N = 92

Bold- significant differences in outcomes at 95% confidence level

Table F136 Effects of radiotherapy on urinary incontinence in adults with adenocarcinoma of the rectum

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Peeters, 2005, ^674^ | 1,861 patients with histologically confirmed adenocarcinoma of the rectum with inferior margin of the tumor had <15cm from the anal verge and below the level of S1 and S2. | 1 Radiotherapy with total dose of 25Gy administered in 5 fractions over 5 to 7 days before total mesorectal excision.; 2 Total mesorectal excision | Self reported urinary and fecal incontinence with 4-point scale from “no, never” to “sometimes” (<1/week), “often” (>1/ week but not every day), and “yes, always” (every day) for time-dependent symptoms and from “no, not at all” to “a little,” “pretty much,” and “very seriously” for time-independent symptoms. | No Intention to treat. Open label.
RCT to examine effects of preoperative short-term radiotherapy in patients treated with total mesorectal excision. | Exclusion criteria: distant metastases, fixed tumors, locally treated (transanal resected) tumors. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 5 years | Loss of followup: 32%, 597 responded to questionnaire. | | | Sample size not justified.

Table F137 Effects of radiotherapy on urinary incontinence in 597 adults (38% women) adenocarcinoma of the rectum (events)

Active | Control | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Peeters, 2005 ^674^ | Total mesorectal excision | Use of pads for urinary incontinence | 67 | 62 | 21.9 | 21.3 | 1.0 (0.8; 1.4)
Radiotherapy with total dose of 25Gy administered in 5 fractions over 5 to 7 days before total mesorectal excision. | Total mesorectal excision | Urinary incontinence | 118 | 109 | 38.6 | 37.5 | 1.0 (0.8; 1.3)
Pollack, 2006 ^675^ | Abdominal rectal resection without preoperative radiotherapy | Urinary incontinence | 29 | 20 | 4.87 | 2.47 | 1.97 (1.13, 3.45) | 42 (322; 17) | 24 (3; 60)E
N = 1,406
56% female
Followup 180
Abdominal rectal resection with preoperative radiotherapy

Table F138 Clinical interventions to reduce risk and progression of urinary incontinence in males with urologic diseases

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Little, 2003 ^676^ | 301 patients 3 with histologically confirmed adenocarcinoma of the prostate and no metastatic disease treated with a four-field box technique to a dose of 46Gy. | 1 Radiation with a four-field box technique to a dose of 70Gy arm.; 2 Radiation with three-dimensional conformal techniques to generate a six-field boost plan of a total dose of 78Gy | Self reported bladder, bowel and sexual function (Fowler) | No intention to treat.
Followup RCT to examine effects of radiotherapy for prostate cancer on urinary incontinence and bowel function. | Exclusion criteria: not reported. | | | Open label.
Duration of followup: 3 years | Response rate 70%. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Srougi, 2005 ^677^ | 100 patients with stage T1c–T2c prostate cancer. | 1 Retropubic radical prostatectomy and vesico-urethral anastomosis with bladder neck mucosal eversion.; 2 Retropubic radical prostatectomy and vesico-urethral anastomosis without bladder neck mucosal eversion | Self reported urinary incontinence (more than one pad/day) | Intention to treat. Double blind. Computer generated randomization. Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
RCT to examine effects of bladder neck mucosal eversion during retropubic radical prostatectomy on urinary incontinence | Exclusion criteria: previous TURP, suprapubic prostatectomy or local radiotherapy; a history of neurological diseases; surgical pathology specimens that showed positive margins at bladder neck. | | | Sample size not justified.
Duration of followup: 6 months | Loss of followup: 5%
Wasson, 1995 ^678^ | 556 men over the age of 54 years with symptoms of benign prostatic hyperplasia. | 1 Transurethral resection of prostate.; 2 Watchful waiting | Urinary symptoms were scored on a scale ranging from 0 to 27 points with the use of a nine-question interview. | Intention-to-treat Open label. Stratified randomization by participating hospital and the severity of disease.
RCT to examine effects of transurethral resection of the prostate or watchful waiting in men with moderate symptoms of benign prostatic hyperplasia. | Exclusion criteria: < 55 years old, previous prostate surgery or radiation treatment, unable to walk, active urinary tract infection not responding to treatment, diagnosed prostate or bladder cancer, residual urinary volume after voiding >350ml, serious medical conditions including uncontrolled diabetes, neurogenic bladder, cirrhosis, active alcoholism, bleeding diathesis, psychosis, and late-stage cardiac or respiratory disease, creatinine concentration >3.0mg/deciliter (265 μmol per liter) | | Persistent incontinence requiring the use of a pad, penile clamp, or condom | Allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 3 years | Loss of followup: 7.4% | | Persistent incontinence requiring the use of a pad, penile clamp, or condom | Sample size not justified.
Van Cangh, 1998 ^679^ | 100 patients with N0M0 prostate cancer treated with radical prostatectomy for locally advanced disease (positive surgical margin, capsular perforation and/or seminal vesicle infiltration). | 1 60Gy. external radiotherapy with 18MV photon beams between 12 and 16 weeks after radical prostatectomy.; 2 Radical prostatectomy alone | A validated modified pad weighing test by the International Continence Society: grade 0 - dry-<1gm. with no pads, grade 1 -“minimal” between 1 and 9gm with 1 to 4 pads, grade 2 -“moderate” 10 – 50gm. with 1 to 4 pads (soaked) and grade 3 “severe”- >50gm. with >4 pads | Intention to treat not stated. Open label.
RCT to examine effects of postoperative radiotherapy for locally advanced disease on urinary incontinence. | Exclusion criteria: not reported. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration of followup: 3 years 24 months | Loss of followup: none | | | Sample size not justified.
Srougi, 2001 ^680^ | 70 patients with clinical stage T1 or T2 prostate cancer who were scheduled for radical prostatectomy and 2 patients with T3a with small prostatic nodules that may have been invading the prostatic capsule but with no established periprostatic tumor extension. | 1 Radical retropubic prostatectomy with bladder neck preservation according to the technique described by Malizia.; 2 Radical retropubic prostatectomy with bladder neck resection according to that of Walsh. | Self reported urinary continence (1 or no protective pad daily) | No Intention to treat.
RCT to examine effects of bladder neck preservation and resection radical retropubic Prostatectomy. | Exclusion criteria: transurethral prostate resection, neurogenic dysfunction of the lower urinary tract. | | | Double blind.
Duration of followup: 6 months | Loss of followup: 1.4% | | | Randomization by the toss of coin. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Ghaly, 2003 ^681^ | Trial 1: 106 low-risk patients, with Gleason Grade 2–6, prostate-specific antigen (PSA) 4–10ng/ml, Trial 2: 108 intermediate-risk patients, with Gleason Grade 7 or higher or PSA of 10–20ng/ml | Trial 1:; 1 I-125 (144Gy, TG-43) I-125 source strength ranged from 0.4 to 0.89mCi (median .55mCi).; 2 Pd-103 (125Gy, NIST-99) and Pd-103 source strength ranged from 1.6 to 2.0mCi (median 2.0mCi). | Self reported urinary incontinence using standard American Urologic Association (AUA) Grade 1: Occasional use of incontinence pads (<1/week), Grade 2: Intermittent use of incontinence pads (<1/day), Grade 3: Regular use of incontinence pad or self-catheterization, Grade 4: Permanent catheter or surgical intervention | No intention to treat.
RCT to examine effects of supplemental beam radiation on prostate brachytherapy-related urinary incontinence. | Exclusion criteria: not reported. | Trial 2:; 1 Pd-103, delivering 90Gy (with 44Gy external beam irradiation delivered with a four-field arrangement, designed to cover the prostate and seminal vesicles with a 2cm margin (reduced to 1.0cm posteriorly).; 2 Pd-103, delivering 115Gy 20Gy external beam irradiation delivered with a four-field arrangement, designed to cover the prostate and seminal vesicles with a 2cm margin (reduced to 1.0cm posteriorly). | | Open label.
Duration of followup: 12 months | Loss of followup: not reported. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Imamoglu, 2005 ^682^ | 45 patients with urinary incontinence for >6 months after radical retropubic prostatectomy, transvesical prostatectomy, and transurethral prostatectomy. | 1 Artificial urethral sphincter implantation.; 2 Macroplastique injection (polydimethylslioxane elastomer implants as the solute component and hydrogel as the carrier) of 5–7.5cc above or around the striated sphincter region of the urethra submucosally. | Minimal incontinence was defined as total number of pads, total weight of pads. | No intention to treat.
RCT to examine effects of macroplastique injection with artificial urinary sphincter implantation on postprostatectomy incontinence. | Exclusion criteria: radiotherapy for prostate carcinoma, minimum bladder capacity of 150cc, detrusor instability or hyperreflexia. | | Continent (“dry”)- no need to use pads; “socially continent” - <1pad; “incontinent”- >1pad/day | Open label.
Duration of followup: 48–60 months | Loss of followup: not reported. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
| | | | Sample size not justified.
Deliveliotis, 2005 ^683^ | 60 potent men <60 years old undergoing bilateral nerve-sparing radical retropubic prostatectomy for clinically localized prostate cancer | 1 10ml of betamethasone cream 0.1% was applied locally to both neurovascular bundles.; 2 Usual neurovascular bundles with no corticoid cream. | Urinary continence - wearing no pads or one pad that remained dry. | Intention to teat not stated. Open label.
RCT to examine effects of applying local steroids to the neurovascular bundles of the prostate after bilateral nerve-sparing radical retropubic prostatectomy. | Exclusion criteria: allergy to steroids, assistance to obtain erections. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
Duration of followup: 12 months | Loss of followup: not reported.
Parsons, 2004 ^684^ | 70 potent men ≤ 60 years old, undergoing bilateral nerve-sparing radical retropubic prostatectomy for clinically localized adenocarcinoma of the prostate. | 1 Methylprednisolone beginning on postoperative day 1: 24mg intravenously on postoperative day 1, 20mg orally on day 2, 16mg orally on day 3, 12mg orally on day 4, 8mg orally on day 5, and 4mg/orally on day 6.; 2 Placebo. | Urinary continence as participant-reported wearing no pads or a single pad that remained dry. | No Intention to treat.
Placebo controlled RCT to examine effects of postoperative methylprednisolone on urinary incontinence after nerve-sparing radical retropubic prostatectomy. | Exclusion criteria: no sexual partner, prior history of an allergic reaction to steroids, prior steroid use, or active use of sildenafil citrate for the treatment of erectile dysfunction. | | | Double blind. Central randomization. Allocation concealment unclear Baseline data did not confirm adequacy of randomization. Sample size justified
Duration: 6 days Duration of followup: 12 months | Loss of followup: 11.4%.
Akakura, 1999 ^685^ | 100 patients 75 years old or younger with a performance status of 0 or 1 and adenocarcinoma of the prostate by needle core biopsy before treatment. | 1 Radical prostatectomy with pelvic lymph node dissection with 300mg of diethylstilbestrol diphosphate/day 8 weeks before surgery or radiation, and continued thereafter.; 2 External beam radiation by linear accelerator with 40 to 50Gy to the whole pelvis and a 20Gy boost to the prostatic area and with 300mg of diethylstilbestrol diphosphate/day 8 weeks before surgery or radiation, and continued thereafter | Urinary incontinence using quality-of-life questionnaire of EORTC. | No Intention to treat.
RCT to examine effects of radical prostatectomy versus radiotherapy with the combination of endocrine therapy on urinary incontinence. | Exclusion criteria: obvious enlargement of pelvic lymph nodes by computed tomography or magnetic resonance imaging. | | | Open label.
Duration of followup: 58.5 months | Loss of followup: 5%. | | | Randomization and allocation concealment not reported. Baseline data did not confirm adequacy of randomization.
| | | | Sample size not justified.
Fransson, 2001 ^686^ | 166 patients with localized prostate carcinoma cytologically or histologically verified as T1a–T2, G1–G2, pN0, and M0. | 1 Radiotherapy with a total dose of 4.8Gy (range, 62.3–70.0Gy) given for 5 days a week, 2Gy per fraction.; 2 Active surveillance | Self reported urinary and fecal incontinence using validated symptom specific self-assessment questionnaire, QUFW94 with values between 0 and 10; 0 - “no problem/very good function” and 10 - “many problems/very bad function.” | No Intention to treat.
RCT to examine effects of radiotherapy for localized prostate carcinoma. Duration of followup: 30–40 months | Exclusion criteria: expected survival <10 years. | | | Open label.
| Loss of followup: 35%. | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
Gupta, 2002 ^687^ | 100 patients with benign prostatic hyperplasia and prostate size >40cc. | 1 Transurethral vesection of the prostate with the thick vapor resection loop using electrosurgical generator with settings of 120 to 150W and 50 to 70W for cutting and coagulating.; 2 Transurethral resection of the prostate with standard wire loop using electrosurgical generator with settings of 70 to 80W and 40 to 50W for cutting and coagulating | Self reported urinary incontinence using International Prostate Symptom Score. | No Intention to treat.
RCT to examine effects of transurethral vesection of the prostate or vapor resection of prostate on urinary incontinence. | Exclusion criteria: finasteride preoperatively, histopathologic adenocarcinoma of the prostate. | | Urodynamic outcomes. | Open label.
Duration of followup: 1 year | Loss of followup: not reported | | | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
Gallucci, 1998 ^688^ | 150 patients with symptoms due to obstructive benign prostatic hypertrophy, urodynamically obstructed. | 1 Transurethral electrovaporization of the prostate.; 2 Transurethral resection of the prostate | I-PSS score. | Intention to treat not stated. Open label.
RCT to examine effects of transurethral electrovaporization of the prostate on urinary incontinence. | Exclusion criteria: complete urinary retention, bladder calculi, neurogenic bladder, prostate weight>70g, bladder cancer, prostate cancer, mental illness. | | Urodynamic outcomes | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
Duration of followup: 12 months | Loss of followup: none
Wilson, 2006 ^689^ | 61 men with bladder outflow obstruction secondary to benign prostatic hyperplasia and prostate size 40–200g, maximum urinary flow rate of 15 ml/second or less, American Urological Association symptom score of ≥8, post-void residual assessment of less than 400ml, and urodynamic Schaffer grade 2 or greater. | 1 Holmium laser enucleation of the prostate with maximum power set at 100W for each case.; 2 Transurethral resection of the prostate with a tungsten cutting wire at 160W cutting and 80W coagulating current | Urinary incontinence using American Urological Association symptom score. | No Intention to treat.
RCT to examine effects of holmium laser enucleation of the prostate or transurethral resection of the prostate for treatment of men with bladder outflow obstruction secondary to benign prostatic hyperplasia. | Exclusion criteria: prostatic carcinoma, catheterization, history of previous urethral or prostatic surgery. | | Maximum urinary flow rates | Open label. Balanced blocked randomization schedule (block of six patients). Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
Duration of followup: 24 months | Loss of followup: 21.3%
Steineck, 2002 ^690^ | 376 men <75 years with life expectancy >10 years (as judged by the attending physician) from the Scandinavian Prostatic Cancer Group Study # 4, with localized prostate cancer (T0d, T1, or T2 and grade 1 or 2 according to the criteria of the World Health Organization Against Cancer). | 1 Radical prostatectomy; 2 Watchful waiting with no advice for initial radical therapy was given | Self reported urinary incontinence using the Spielberger's Trait Measure from the State-Trait Anxiety Inventory | Intention-to-treat. Open label. Randomization not described in this paper.
RCT to examine the effects of radical prostatectomy or watchful waiting of incontinence in patients with localized cancer. | Exclusion criteria: previously diagnosed cancer, concurrent disorder considered to increase the risk of operative mortality, or inability to comply with treatment and followup. Loss of follow up: 13.3% | | | Allocation concealment not clear. Baseline data did not confirm the adequacy of randomization.
Duration of follow up: 12 months after surgery and 14 months after randomization | | | | Adjustment for age, time from randomization to completion of the questionnaire, date of responding to the questionnaire, and educational level did not effect the relative risks

Table F139 Effects of clinical intervention on urinary continence in males (events) (sorted by rate of urinary continence after active treatment, from highest to lowest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI)
Sample
Srougi, 2001 ^680^ | Radical Retropubic prostatectomy with bladder neck preservation according to the technique described by Malizia | Radical Retropubic prostatectomy with bladder neck resection according to that of Walsh et. al. | Urinary continence using 1 or no pad daily | 30 | 36 | 96.8 | 92.3 | 1.0 (0.9; 1.2)
N = 70
Imamoglu, 2005 ^682^ | Macroplastique injection (polydimethylslioxane elastomer implants as the solute component and hydrogel as the carrier) of 5–7.5cc above or around the striated sphincter region of the urethra submucosally. | Artificial urethral sphincter implantation. | Self reported urinary continence in patients with minimal baseline incontinence | 8 | 10 | 80.0 | 90.9 | 0.9 (0.6; 1.3)
N = 24
Van Cangh, 1998 ^679^ | 60Gy. external radiotherapy with 18MV photon beams 12 – 16 weeks after radical prostatectomy | Radical prostatectomy alone | Complete Urinary continence | 37 | 43 | 77.0 | 83.0 | 0.9 (0.8; 1.1)
N = 100
Imamoglu, 2005 ^682^ | Macroplastique injection (polydimethylslioxane elastomer implants as the solute component and hydrogel as the carrier) of 5–7.5cc above or around the striated sphincter region of the urethra submucosally. | Artificial urethral sphincter implantation. | “socially continent” - <1pad/day in patients with total baseline incontinence | 5 | 2 | 38.5 | 18.2 | 2.1 (0.5; 8.8)
N = 24 | | | “socially continent” - <1pad/day in patients with minimal baseline incontinence | 1 | 1 | 10.0 | 9.1 | 1.1 (0.1; 15.4)

Table F140 Effects of clinical interventions on urinary incontinence in males (events) (sorted by rate of urinary incontinence after active treatment, from lowest to highest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Gupta*, 2002 ^687^ | Transurethral vesection of the prostate with the thick vapor resection loop using electrosurgical generator with settings of 120 to 150W and 50 to 70W for cutting and coagulating | Transurethral vesection of the prostate with standard wire loop using electrosurgical generator with settings of 70 to 80W and 40 to 50W for cutting and coagulating | Self reported urinary incontinence | 0 | 2 | 0.0 | 4.0 | 0.2 (0.0; 4.1)
N = 100
Gallucci*, 1998 ^688^ | Transurethral resection of the prostate | Transurethral electro vaporization of the prostate | Transient stress urinary incontinence | 0 | 13 | 0.1 | 18.6 | 0.0 (0.0; 0.5) | 5 (5; 12) | 185 (86;1 86; 86)A
N = 150
Ghaly, 2003 ^681^ | I-125 (144Gy, TG-43) I-125 source strength ranged from 0.4 to 0.89mCi (median .55mCi) | Pd-103 (125Gy, NIST-99) and Pd-103 source strength ranged from 1.6 to 2.0mCi (median 2.0mCi) | Regular use of incontinence pad or self-catheterization incontinence pad or self-catheterization for urinary incontinence | 1 | 5 | 1.0 | 10.0 | 0.2 (0.0; 1.5)
N = 54
Wasson*, 1995 ^678^ | Transurethral resection of prostate | Watchful waiting | High residual urinary volume | 3 | 16 | 1.1 | 5.8 | 0.2 (0.1; 0.6) | 21 (18; 46) | 47 (22; 55)A
N = 556
Gallucci*, 1998 ^688^ | Transurethral resection of the prostate | Transurethral electro vaporization of the prostate | Stress urinary incontinence | 1 | 4 | 1.3 | 5.7 | 0.2 (0.0; 1.9)
N = 150
Wasson*, 1995 ^678^ | Transurethral resection of prostate | Watchful waiting | Persistent urinary incontinence | 4 | 4 | 1.4 | 1.4 | 1.0 (0.2; 3.9)
N = 556
Van Cangh, 1998 ^679^ | 60Gy. external radiotherapy with 18MV photon beams 12 – 16 weeks after radical prostatectomy | Radical prostatectomy alone | Severe urinary incontinence with implantation of artificial sphincter | 1 | 1 | 2.1 | 1.9 | 1.1 (0.1; 16.8)
N = 100
Gallucci*, 1998 ^688^ | Transurethral resection of the prostate | Transurethral electro vaporization of the prostate | Urge urinary incontinence | 2 | 0 | 2.5 | 0.1 | 4.4 (0.2; 89.8)
N = 150
Wilson*, 2006 ^689^ | Holmium laser enucleation of the prostate with maximum power set at 100W for each case | Transurethral resection of the prostate with a tungsten cutting wire at 160W cutting and 80W coagulating current | Incident of stress incontinence | 1 | 0 | 3.3 | 0.1 | 3.0 (0.1; 70.8)
N = 61 | | | Incident of urge incontinence | 1 | 0 | 3.3 | 0.1 | 3.0 (0.1; 70.8)
Little, 2003 ^676^ | Radiation with a four-field box technique to a dose of 70Gy arm | Radiation with three-dimensional conformal techniques to generate a six-field boost plan of a total dose of 78Gy | Wears protection for urinary incontinence | 4 | 5 | 3.7 | 4.9 | 0.8 (0.2; 2.8)
N = 301
Ghaly, 2003 ^681^ | Pd-103, delivering 90Gy (with 44Gy external beam irradiation delivered with a four-field arrangement, designed to cover the prostate and seminal vesicles with a 2cm margin (reduced to 1.0cm posteriorly). | Pd-103, delivering 115Gy, 20Gy external beam irradiation delivered with a four-field arrangement, designed to cover the prostate and seminal vesicles with a 2cm margin (reduced to 1.0cm posteriorly). | Regular use of incontinence pad or self-catheterization incontinence pad or self-catheterization incontinence pad or self-catheterization for urinary incontinence | 3 | 5 | 5.0 | 10.0 | 0.5 (0.1; 2.1)
N = 108
Little, 2003 ^676^ | Radiation with a four-field box technique to a dose of 70Gy arm | Radiation with three-dimensional conformal techniques to generate a six-field boost plan of a total dose of 78Gy | Nocturia present: 4–5 times/night | 7 | 7 | 6.5 | 6.8 | 1.0 (0.3; 2.6)
N = 301 | | | Stress urinary incontinence: Leakage with cough/sneeze | 7 | 7 | 6.5 | 6.8 | 1.0 (0.3; 2.6)
| | | Urinary Incontinence amount: >1 Tablespoon/d ay | 7 | 2 | 6.5 | 1.9 | 3.3 (0.7; 15.7)
Steineck, 2002 ^690^ | Radical prostatectomy | Watchful waiting | Great distress | 14 | 5 | 7.41* | 2.67 | 2.77 (1.02; 7.54)
N = 376 | | | Urinary problems affecting sexual life:Moderately or severely | 15 | 5 | 7.94* | 2.67 | 2.97 (1.10; 8.00) | 19 (5; 370) | 53 (3; 187)E
12 months | | | Great distress from all urinary symptoms | 15 | 8 | 7.94* | 4.28 | 1.86 (0.81; 4.27)
| | | Regular dependence on diaper or urine bag | 23 | 1 | 12.17* | 0.53 | 22.76 (3.10; 166.79) | 9 (1; 89) | 116 (11; 887)E
| | | Moderate or severe leakage | 30 | 3 | 15.87* | 1.60 | 9.89 (3.07; 31.86) | 7 (2;30) | 143 (33; 495)E
Fransson, 2001 ^686^ | Radiotherapy with a total dose of 4.8Gy (range, 62.3–70.0Gy) given for 5 days a week, 2Gy per fraction. | Active surveillance | Use of pad for urinary incontinence | 10 | 1 | 17.5 | 2.1 | 8.3 (1.1; 62.6) | 6 (1;470) | 154 (2; 1,294)E
N = 166
Imamoglu, 2005 ^682^ | Macroplastique injection (polydimethylslioxane elastomer implants as the solute component and hydrogel as the carrier) of 5–7.5cc above or around the striated sphincter region of the urethra submucosally | Artificial urethral sphincter implantation. | Self reported urinary continence in patients with total baseline incontinence | 3 | 8 | 23.1 | 72.7 | 0.3 (0.1; 0.9) | 2 (2; 16) | 496 (64; 647)A
N = 24
Steineck, 2002 ^690^ | Radical prostatectomy | Watchful waiting | Moderate or great distress from all urinary symptoms | 44 | 28 | 23.28* | 14.97 | 1.55 (1.01; 2.39) | 12 (5; 518) | 83 (2; 208)E
N = 376 | | | Moderate or great distress from urinary leakage | 47 | 15 | 24.87* | 8.02 | 3.10 (1.80; 5.35) | 6 (3;16) | 168 (64; 349) E
12 months
Little, 2003 ^676^ | Radiation with a four-field box technique to a dose of 70Gy arm | Radiation with three-dimensional conformal techniques to generate a six-field boost plan of a total dose of 78Gy | Urinary Incontinence frequency: >once per day | 26 | 30 | 24.1 | 29.1 | 0.8 (0.5; 1.3)
N = 301 | | | Urinary Incontinence present | 40 | 32 | 37.0 | 31.1 | 1.2 (0.8; 1.7)
Steineck, 2002 ^690^ | Radical prostatectomy | Watchful waiting | Regular dependence on some form of protective aid | 71 | 16 | 37.57* | 8.56 | 4.39 (2.65; 7.26) | 3 (2;7) | 290 (142; 536)E
N = 376
12 months
Imamoglu, 2005 ^682^ | Macroplastique injection (polydimethylslioxane elastomer implants as the solute component and hydrogel as the carrier) of 5–7.5cc above or around the striated sphincter region of the urethra submucosally. | Artificial urethral sphincter implantation. | Urinary incontinence: >1pad/day in patients with total baseline incontinence | 5 | 1 | 38.5 | 9.1 | 4.2 (0.6; 31.0)
N = 24
Akakura, 1999 ^685^ | Radical prostatectomy with pelvic lymph node dissection with 300mg of diethylstilbestrol diphosphate/day 8 weeks before surgery or radiation, and continued thereafter | External beam radiation by linear accelerator with 40 to 50Gy to the whole pelvis and a 20Gy boost to the prostatic area and with 300mg of diethylstilbestrol diphosphate/day 8 weeks before surgery or radiation, and continued thereafter | Urinary incontinence using quality-of-life questionnaire of EORTC | 22 | 0 | 40.0 | 1.0 | 35.5 (2.2; 569.8) | 3 (0; 82) | 390 (12; 5,688)E
N = 100
Steineck, 2002 ^690^ | Radical prostatectomy | Watchful waiting | Leakage once a week or more often | 80 | 33 | 42.33* | 17.65 | 2.40 (1.69; 3.41) | 4 (2;8) | 247 (121; 425)E
N = 376
12 months
Little, 2003 ^676^ | Radiation with a four-field box technique to a dose of 70Gy arm | Radiation with three-dimensional conformal techniques to generate a six-field boost plan of a total dose of 78Gy | Urge urinary incontinence: Leakage with full bladder | 47 | 37 | 43.5 | 35.9 | 1.2 (0.9; 1.7)
N = 301
Wilson*, 2006 ^689^ | Holmium laser enucleation of the prostate with maximum power set at 100W for each case | Transurethral resection of the prostate with a tungsten cutting wire at 160W cutting and 80W coagulating current | Self reported regained urinary incontinence | 15 | 8 | 50.0 | 26.7 | 1.9 (0.9; 3.7)
N = 61
Steineck, 2002 ^690^ | Radical prostatectomy | Watchful waiting | At least some leakage | 101 | 53 | 53.44* | 28.34 | 1.89 (1.45; 2.45) | 4 (2;8) | 251 (127; 412)E
N = 376
12 months
Sroug, 2005 ^677^ | Retropubic radical prostatectomy and vesico-urethral anastomosis with bladder neck mucosal eversion | Retropubic radical prostatectomy and vesico-urethral anastomosis without bladder neck mucosal eversion | Urinary incontinence | 44 | 43 | 91.7 | 91.5 | 1.0 (0.9; 1.1)
N = 100

Bold- significant differences in outcomes at 95% confidence level;

* - the patients were continent at baseline (no baseline UI reported);

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F141 Effect of surgical intervention on perceived urinary incontinence in males (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95%CI) | Change % From Control (95%CI)
Sample
Ghaly, 2003 ^681^ | I-125 (144Gy, TG-43) I-125 source strength ranged from 0.4 to 0.89mCi (median .55mCi) | Pd-103 (125Gy, NIST-99) And Pd-103 source strength ranged from 1.6 to 2.0mCi (median 2.0mCi) | Self reported urinary scores American Urologic Association and Radiation Therapy Oncology Group criteria | 0.2 ± 0.0 | 0.1 ± 0.0 | 11.0 (9.5; 12.5)
N = 54
Ghaly, 2003 ^681^ | Pd-103, delivering 90Gy (with 44Gy external beam irradiation delivered with a four-field arrangement, designed to cover the prostate and seminal vesicles with a 2cm margin (reduced to 1.0cm posteriorly). | Pd-103, delivering 115Gy 20Gy external beam irradiation delivered with a four-field arrangement, designed to cover the prostate and seminal vesicles with a 2cm margin (reduced to 1.0cm posteriorly). | Regular use of incontinence pad or self-catheterization incontinence pad or self-catheterization incontinence pad or self-catheterization for urinary incontinence | 0.3 ± 0.1 | 0.3 ± 0.1 | 0.0 (-0.4; 0.4) | 0.0 (-151.1; 151.1)
N = 108
Wasson, 1995 ^678^ | Transurethral resection of prostate | Watchful waiting | Bother from urinary difficulties on a scale ranging from 0 (greatest impairment) to 100 (least impairment). | 75.7± 23.9 | 57. ± 28.3 | 0.7 (0.5; 0.9) | 1.2 (0.9; 1.5)
N = 556
Wilson2006 ^689^ | Holmium laser enucleation of the prostate with maximum power set at 100W for each case | Transurethral resection of the prostate with a tungsten cutting wire at 160W cutting and 80W coagulating current | Urinary incontinence using American Urological Association symptom score | 6.1 ± 1.0 | 5.2 ± 0.8 | 1.0 (0.5; 1.5) | 19.1 (8.8; 29.4)
N = 61
Fransson, 2001 ^686^ | Radiotherapy with a total dose of 4.8Gy (range, 62.3–70.0Gy) given for 5 days a week, 2Gy per fraction. | Active surveillance | Self reported urinary incontinence0 - “no problem/very good function” and 10 - “many problems/very bad function.” | 1.5 ± 2.7 | 0.6 ± 1.4 | 0.4 (0.0; 0.8) | 68.4 (4.6; 132.2)
N = 166
Wilson, 2006 ^689^ | Holmium laser enucleation of the prostate with maximum power set at 100W for each case | Transurethral resection of the prostate with a tungsten cutting wire at 160W cutting and 80W coagulating current | Urinary incontinence using American Urological Association symptom score | 4.6 ± 0.7 | 4.7 ± 0.9 | -0.1 (-0.6; 0.4) | -2.6 (-13.4; 8.1)
N = 61

Bold- significant differences in outcomes at 95% confidence level

Table F142 Effect of surgical interventions on progression of urinary incontinence in males (urodynamic measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95%CI) | Change % From Control (95%CI)
Sample
Wasson, 1995 ^678^ | Transurethral resection of prostate | Watchful waiting | Peak urinary-flow rate (ml/sec) | 17.8 ± 9.1 | 12.7 ± 7.6 | 0.6 (0.4; 0.8) | 4.8 (3.4; 6.1)
N = 556*
Wilson*, 2006 ^689^ | Holmium laser enucleation of the prostate with maximum power set at 100W for each case | Transurethral resection of the prostate with a tungsten cutting wire at 160W cutting and 80W coagulating current | Maximum urinary flow rate | 21.0 ± 2.0 | 19.3 ± 2.2 | 0.8 (0.3; 1.3) | 4.2 (1.5; 6.9)
N = 61 | | | Maximum urinary flow rate | 21.3 ± 2.1 | 18.9 ± 2.8 | 1.0 (0.4; 1.5) | 5.1 (2.3; 8.0)
Gallucci*, 1998 ^688^ | Transurethral resection of the prostate | Transurethral electro vaporization of the prostate | Post void residual volume (ml) | 3.2 ± 17.5 | 5.2 ± 20.4 | -0.1 (-0.4; 0.2) | -2.1 (-8.2; 4.0)
N = 150
Wasson, 1995 ^678^ | Transurethral resection of prostate | Watchful waiting | Residual urinary volume (ml) | 51.0 ± 54.0 | 72.0 ± 73.0 | -0.3 (-0.5; -0.2) | -0.5 (-0.7; -0.2)
N = 556

* Patients with benign prostate diseases;

Bold - significant differences in outcomes at 95% confidence level

Table F143 Effects of hormone replacement therapy on risk and progression of urinary incontinence in women

Study | Participants | | Clinical Interventions | Outcomes | Quality Issues
Goldstein, 2005 ^691^ | 619 women age 40 – 60 years, postmenopausal (naturally or surgically), with a hysterectomy no more than 15 years before beginning study, serum estradiol ≤73pmol/l (≤ 20pg/ml) and follicle-stimulating hormone ≥40 IU/l. | | 1 Raloxifene HCl 60mg/day.; 2 Raloxifene HCl 150mg/day.; 3 Conjugated equine estrogen 0.625mg/day; 4 Placebo supplement of 400/600mg/day elemental calcium | Self-reported new or worsening urinary incontinence rated as “mild,” “moderate,” or “severe.” | Intention to treat.
Placebo-controlled | Exclusion criteria: history of breast carcinoma or estrogen-dependent tumors, cancer within the last 5 years (except excised skin cancers), estrogen therapy (other than vaginal estrogens), progestin, androgen, calcitonin, or systemic corticosteroids within the previous 6 months, a history of thromboembolic disorders or diabetes mellitus or other endocrine disorders requiring therapy (except thyroid hormone replacement), or serious postmenopausal symptoms. | | | | Double-blind.
RCT to examine the efficacy and safety of raloxifene for osteoporosis prevention in postmenopausal women. | Loss of followup 4.5%; Discontinuation - adverse events (17.6%), personal reasons (11.0%). The percentage of women missing at least 20% of study medication was similar across the groups (10% to 14%; P = 0.71) | | | | Randomized block design (block size = 4); baseline data confirmed adequate randomization.
Duration: 36 months | | | | | No justification of sample size.
| | | | | Incontinence - secondary outcome.
Vardy, 2003 ^692^ | 100 healthy white postmenopausal women > 1 year from last menstrual period, age 45 – 70 years, with normal mammogram within 6 months of the study and free from any serious acute or chronic medical disorder. | | 1 0.625mg/day conjugated equine estrogen; 2 20mgday tamoxifen; 3 60mg/day raloxifene; 4 Placebo | Weekly symptom diaries to report urinary urgency, frequency, and incontinence ranked as “new,” “worsened,” “improved,” or “remained the same.” | Intention to treat not stated. Double-blind. Allocation concealment unclear. Subjects had Incontinence at baseline (32.7%) with unknown distribution in the groups.
Placebo-controlled | Exclusion criteria: previous hysterectomy or reconstructive pelvic surgery, intake of estrogen, calcitonin, fluoride steroid, or diuretic therapy within 6 months, contraindication to hormone replacement therapy or either SERM | | | Pelvic organ prolapse quantitation. | No justification for sample size.
RCT to examine urogenital effects of raloxifene, tamoxifen, conjugated equine estrogen, and placebo in healthy postmenopausal women | | | | Urethral axis deflection by cotton swab.
Duration: 5 month
Warming, 2003 ^693^ | 234 generally healthy women, age 45 – 65 years, at least 1 year postmenopausal and with an intact uterus. | | 1 Levormeloxifene at 1.25, 5, 10, or 20mg/per day,; 2 Continuous combined HRT (17β-oestradiol 1 mg and norethisterone acetate 0.5mg per day).; 3 Placebo: calcium supplement 500/mg/day | Self-reported urinary incontinence (including worsening of a previously existing condition). | Intention to treat not stated. Double-blind. Allocation Concealment unclear. No justification for sample size.
Placebo-controlled | Exclusion criteria: known or suspected acute or chronic disease, or taking medication known to interfere with the results of the study. | | | Utero-vaginal prolapse detected by transvaginal ultrasonography | Outcomes reported independent of the dose of levormeloxifene.
RCT To examine the adverse events after 12 month treatment with levormeloxifene and followup of 12 months without treatment. | Completed 12 months treatment | 77%
| Withdrawn at the end of 12 months | 0.7%
| Included in followup | 78%
| Withdrawn during followup (adverse event) | 0.3%
| Completed 12-month followup | 77%
Steinauer, 2005 ^694^ | 1,208 postmenopausal women age <80 years, with coronary heart disease and an intact uterus who reported no loss of urine in the previous 7 days at baseline | | 1 Conjugated estrogen (0.625mg) and medroxy progesterone acetate (2.5mg) in 1 pill; 2 Identical looking placebo | Self-reported urinary incontinence (including worsening of a previously existing condition). | Intention to treat.
Placebo-controlled | Loss of followup: 1 participant taking hormone therapy discontinued due to adverse reactions, 58 died, and 5 failed to return, and 11 were lost to followup for other reasons. | | | Stress incontinence: unintentionally leaking some urine with coughing, sneezing, straining, laughing, or lifting | Double-blind.
RCT The Heart Estrogen/progestin Replacement Study to examine HRT for the prevention of heart disease events in women with established heart disease | Placebo group: 60 died, 5 failed to return, and 12 were lost to followup for other reasons. | | | Urge incontinence: unintentionally leaking some urine before getting to the bathroom. | Randomization in each of 20 clinical centers using randomly permuted blocks of 4. Groups of continent women were comparable at baseline. No justification for sample size Incontinence - secondary outcome.
Duration: 4.2 years | The compliance rates were 80% in the placebo group and 68% in the hormone groups | | | Weekly incontinence >1 episodes in the previous week
Hendrix, 2005 ^695^ | 25,597 women age 50 to 79 years, postmenopausal, and likely to reside in the study area for 3 years with adherence rate of 80% or greater during 4-week placebo run-in. | | 1 0.625mg/day conjugated equine estrogen plus; 2 5mg/day of medroxyprogester one acetate; 2 0.625mg/day conjugated equine estrogen; 3 Placebo estrogen plus progestin; 4 Placebo estrogen alone | Self-reported incident at 1 year. | Intention to treat Double-blind.
Placebo-controlled RCT. | Exclusion criteria: breast cancer, other invasive cancer in the last 10 years, venous thromboembolism, hypertriglyceridemia, medical condition likely to result in death within 3 years, or unwillingness to be randomized to placebo, severe menopausal symptoms. | | | Prevalent incontinence: ever leaking any amount of urine. | Central randomization at a 1:1 ratio. The study pill bottles had unique bar codes and computer-based selection to enable double-blinded dispensing.
Women's Health Initiative Study to examine effects of HRT in preventing coronary heart disease and hip fractures in postmenopausal women. | Loss of followup: in 1st group 0.2% deceased and 0.1% lost to followup, 9.7% and 6.6% in placebo stopped taking study pills for various reasons. | | | Stress incontinence: leaking of urine during a cough, laugh, sneeze, lift, stand up or exercise. | Incontinence - secondary outcome. Baseline data confirmed adequacy of randomization.
Duration: 1 year | Adherence 74% and 81% in the placebo group at 1 year. | | | Urge incontinence - leaking of urine before getting to the toilet.
| 2nd active group: 0.4% deceased, 8.4% and 8.0% in placebo stopped taking study pills for various reasons. Adherence: 77.4% and 81.4% in placebo at 1 year. | | | Mixed incontinence - a combination of stress and urge symptoms.
| | | | Continence - no leaking urine once during the past year or no longer leaking urine. Changes in self-reported frequency, amount (barely noticeable, soaked underpants, soaked through to outer clothing), limitations in daily activities (never to very often), and bother/disturbance (not at all to very disturbing) as better, same, or worse
Vestergaard, 2003 ^696^ | 1,006 women age (45–58 years) from a random sample of 47,720 with intact uterus and 3–24 months past last menstrual bleeding or experiencing perimenopausal symptoms (including irregular menstruations), the latter combined with elevated serum follicular stimulating hormone (FSH), and hysterectomised women age 45–52 years with elevated FSH. | | 1 Sequential oestrogen and progestogen (28 day cycle: 2mg oestradiol for the first 12 days, 2mg oestradiol and 1mg norethisterone acetate for the next 10 days followed by 1mg oestradiol for 6 days, in women with intact uterus; 2 Continuous oestradiol 2mg/day in hysterectomised women; 3 No HRT | Self reported presence of incontinence. | Intention to treat.
RCT of The Danish Osteoporosis Prevention Study (DOPS) to examine effects of HRT for primary prevention of osteoporotic fractures in healthy recently postmenopausal women. | Exclusion criteria: (1) Metabolic bone disease, including osteoporosis defined as nontraumatic vertebral fractures on X-ray. (2) Current oestrogen use or oestrogen use within the past 3 months. (3) Current or past treatment with glucocorticoids <6 months. (4) Current or past malignancy. (5) Newly diagnosed or uncontrolled chronic disease. (6) Alcohol or drug addiction | | | Symptom scores were recorded on a modified Greene scale (range 0–4 with 0 equaling no symptoms, and 4 maximal symptoms). | Open label. Group 1 and 2 were block-randomized in groups of ten by the envelope method. Baseline data providing difference between treatment regimens not analyzed. No justification for sample size.
Duration: 5 years. | | | | | Outcomes reported in two groups: HRT vs. No HRT.
Goldstein, 2002 ^697^ | 2,924 generally healthy women age ≥65 years, with diagnosed osteoporosis. | | 1 0.5 or 1.25mg of levormeloxifene; 2 Placebo: Daily dietary supplement of 800/1000mg calcium and 400IU vitamin D | Self reported new urinary incontinence, micturition frequency, and the frequency of urinary incontinence as an adverse event | Intention to treat not stated. Double-blind. No justification for the sample size.
Placebo-controlled | Exclusion criteria: known or suspected hormone-dependent or other cancers, previous myocardial infarctions, deep venous thrombosis, corticosteroid treatment, or endometrial thickness >8mm, as gauged by transvaginal ultrasound scanning. | | | | Allocation concealment unclear. Only a subset of the data was ever validated; no summary statistics were calculated for demographic data.
RCT to examine different doses of levormeloxifene for the treatment of postmenopausal osteoporosis and prevention of vertebral compression fractures in elderly women. | Loss of followup: 9.6% before the trial was discontinued because of adverse events and other reasons that included noncompliance | | | | No justification for sample size.
Planned duration: 3 years, stopped after 10 months
Kok, 1999 ^698^ | 102 healthy postmenopausal nonhysterectomized women amenorrhoeic for at least 12 months with postmenopausal status confirmed by elevated serum FSH (>35 IU/l) and LH (>10 IU/l) levels and decreased oestradiol (<120pmol/l) levels. | | 2mg 17 beta-estradiol continuously combined with one of four doses (2.5, 5, 10, or 15mg) of dydrogesterone. | Diurnal micturition - number of reported voids during the day, frequency as more than seven times a day. Nocturnal micturition - number of times one has to get up to void at night and nocturia, a condition with more than two voids a night | Intention to treat not stated. Double-blind.
Randomized non controlled clinical trial to examine effects of HRT for endometrial protection in healthy postmenopausal women. | Loss of followup: 7% stopped HRT due to irregular bleeding episodes, lack of medication compliance and lack of improvement of climacterial complaints other than urinary complaints | | No placebo group: before-after comparison in one active group | | Randomization with permuted blocks Allocation concealment unclear.
Duration: 6 months | | | | | Nonparametric tests for randomization bias.
| | | | | Baseline data confirmed the adequacy of randomization.
| | | | | No justification for sample size.
Long, 2006 ^699^ | 57 hysterectomised, postmenopausal women with serum FSH level of >40 IU/l and an E_2_ level of <20pg/ml. | | 1 Oral 0.625mg of conjugated equine estrogen per tablet; 2 Topical 0.625mg conjugated equine estrogen per 1g vaginal cream | The Bristol Female Lower Urinary Tract Symptoms | No Intention to treat. Two investigators were blind to each other's results.
RCT to examine effects of oral and vaginal estrogen therapy on the lower urinary tract in postmenopausal women with prior hysterectomy | Exclusion criteria: vasoactive medication, prior breast or endometrial cancer, diabetes, anemia (Hg <10g/dl), urinary tract infection, use of HRT in the previous 12 months, and non visible periurethral vessels during ultrasonographic assessment. | | | Questionnaires and standardized urinary diary to report episodes of total, urge, and stress urinary incontinence and episodes of stress urinary incontinence/week | Allocation concealment unclear. No justification for the sample size. No comparison provided between groups, before/after treatments only.
Duration: 3 months | 16 patients interrupting ET were excluded from the analysis
Jackson, 2002 ^700^ | 67 postmenopausal women with urodynamic diagnosis of genuine stress incontinence without symptomatic prolapse. 55 consented to vaginal biopsy and were randomized. | | 1 Oestradiol valerate 2mg/day.; 2 Placebo | Clinical improvement in urinary incontinence diagnosed with urodynamic tests | No Intention to treat. Double-blind.
Placebo-controlled | Loss of followup: 3 dropped the trial due to personal reasons, vaginal discharge, and advice from general practitioner. 3 preferred not to undergo a second biopsy. | | | | Randomization (computer generated simple random sampling) by hospital pharmacy.
RCT to examine effects of HRT in improvement of quantity or quality, of pelvic collagen in postmenopausal women. | 49 women included in the analysis | | | | Allocation concealment unclear. Sample size justified for the primary outcome-% of total collagen.
Duration: 6 months | | | | | No baseline comparison reported.
Fantl, 1996 ^701^ | 83 hypo estrogenic women 45 years or older, who reported involuntary loss of urine at least once a week. | | 1 Conjugated equine estrogens (0.625mg) and medroxyprogesterone (10mg) cyclically.; 2 Placebo | Number of incontinent episodes/week recorded in standardized urinary diary. | Intention to treat not stated. Double-blind. Blocked randomization stratified by baseline severity of urinary incontinence was performed at each site with sets of sequenced, sealed, opaque envelopes, each containing the bottle number to be given to an individual patient.
Placebo-controlled | Exclusion criteria: institutionalization, permanent catheterization, impaired mental status, functional disability limiting use of the toilet (alone or assisted), neuropathic or uncontrolled metabolic conditions, chronic urinary tract infection, reversible causes of urinary incontinence, or major contraindications for the use of estrogen therapy. | | | Amount of fluid loss (measured by a standardized pad test) and the number of voluntary diurnal and nocturnal micturition per week obtained with the same diary technique. | Sample size not justified.
RCT to examine efficacy of cyclic postmenopausal hormone replacement in treating urinary incontinence in hypo estrogenic women. | Loss of followup: none
Duration: 3 months
Jackson,1999 ^702^ | 67 post-menopausal women with genuine stress incontinence confirmed with urodynamic evaluation, not taking hormone replacement therapy. | | 1 Oestradiol valerate 2mg daily.; 2 Placebo | Urinary diary to report subjective incontinence symptoms, frequency, and severity. Standard perineal pad test, and urodynamic evaluation to measure functional capacity, detrusor pressure, voiding flow, post-micturition residual, and volume at first desire to micturate | Intention to treat not stated. Double-blind.
Placebo-controlled | Exclusion criteria: history of cancer of the endometrium, liver, or breast; endometrium more than 4mm thick. | | | | Randomization by hospital pharmacy with computer generated blocks (5 oestradiol and 5 placebos). Baseline data confirmed the adequacy of randomization.
RCT to examine effect of hormone replacement therapy on post-menopausal urinary stress incontinence | Loss of followup: 5 women did not complete the trial; one woman underwent surgical treatment | | | | Sample size justified.
Duration: 6 months
Ishiko, 2001 ^703^ | 73 women with postmenopausal stress incontinence. | | 1 Combination of estriol (1 mg/day) and pelvic floor muscle exercise; 2 Pelvic floor muscle exercise alone | Standardized questionnaire to report severity of stress incontinence scored ranked mild (10–17), moderate (18–23), and severe (24–26) incontinence. | No Intention to treat. Open label.
RCT to examine effects of combination pelvic floor muscle exercise and estriol on postmenopausal stress incontinence. | Exclusion criteria: urge or mixed incontinence. | | | Continent rate in groups | Allocation concealment unclear. Baseline data confirmed the adequacy of randomization. No justification for sample size.
Duration: 2 years | Loss of followup: 6 women withdrew for personal reasons, one due to adverse effects
Rufford, 2003 ^704^ | 40 postmenopausal women (>1 year at menopause) with the ‘urge syndrome’; with estradiol <150pmol/l in women after hysterectomy with no contraindication for estrogen therapy. | | 1 25mg 17 beta-estradiol implant subcutaneous tissue.; 2 Placebo implant | Urodynamic outcome; frequency volume chart with self reported incontinence symptoms | No intention to treat. Double blind.
Placebo-controlled | Exclusion criteria: medication treatment of urge syndrome, diuretics, HRT, history of diabetes, endometrial thickness >4mm urinary tract infection, pelvic masses and urogenital prolapse. | | | | Allocation concealment adequate. Baseline data confirmed the adequacy of randomization.
RCT to examine the effect of systemic estrogen on the ‘urge syndrome’ in postmenopausal women. | Loss of followup: 11 women decided not to participate | | | | Sample size justified.
Duration: 6 months
Ahlstrom, 1990 ^705^ | 29 postmenopausal women with slight to severe stress urinary incontinence and estrogen deficiency symptoms confirmed during urodynamic exam. | | 1 Estriol 4mg/day and 50mg phenylpropanolamine twice daily.; 2 Estriol 4mg/day and placebo | Urodynamic outcomes: mean maximum urethral pressure, mean maximum urethral closure, mean functional urethral length, and abdominal pressure transmission ratio to the urethra | No intention to treat. Double blind.
Placebo-controlled crossover RCT to examine effects of estrogen with alpha-adreno-receptor agonist compared to estrogen alone on incontinence in postmenopausal women. | Exclusion criteria: use of hypotensives, neuroleptics, sedatives, antihistamines, ephedrine, HRT, bacteriuria, history of breast cancer. | | | | Allocation concealment unclear. Baseline data not provided but reported as balanced.
Duration: 6 weeks | Loss of followup: none, one woman was excluded from the analysis due to failure in medication | | | | Sample size not justified.
Cardozo, 1993 ^706^ | 64 postmenopausal women with symptoms of sensory and motor urge incontinence, at least 1 year without menstruation, FSH>40UI/l and oestradiol <220pmol/l. | | 3mg oral oestriol/day. | Self reported incontinence episodes/day. | No intention to treat. Double-blind.
Placebo-controlled multicenter RCT to examine effects of oestriol in treatment of postmenopausal sensory and motor urge incontinence. | Exclusion criteria: voiding difficulties, incontinence before menopause, pelvic anatomical defect requiring surgery, neurological disease, medications to treat incontinence. | | Placebo | Urodynamic outcomes. | Central stratified by incontinence randomization.
Duration: 3 months | Loss of followup: 27% | | | | Allocation concealment adequate. Baseline data confirmed the adequacy of randomization.
| | | | | Sample size justified.
Kinn, 1988 ^707^ | 36 women 1 or more years after post-menopause with stress incontinence verified with urodynamic examination. | | 1 Oral estriol (Triovex, 2mg × 1) + Placebo.; 2 Phenylpropanolamine (Kontexin, 50mg × 2) + Placebo.; 3 Combination of oral estriol and phenylpropanolamine | Micturition schedule recorded in the diary. | Intention to treat.
Cross-over RCT to examine effects of oral estriol, phenylpropanolamine, and its combination on stress urinary incontinence in postmenopausal women | Exclusion criteria: use of hormones, alpha-agonists and alpha-antagonists, urinary tract infection. | | | Urodynamic outcomes. | Single blind (subjects).
Duration: 4 weeks/treatment | Loss of followup: 16.6% | | | | Randomization and allocation concealment not reported. Baseline data not reported but stated the same in the treatment groups.
| | | | | Sample size not justified.
Wilson, 1987 ^708^ | 36 postmenopausal women with stress incontinence confirmed with urodynamic examination. | | 1 Cyclical treatment with piperazine oestrone sulphate; 2 Placebo | 7-day bladder charts, urethral pressure profiles (UPP) | No intention to treat. Double-blind.
Placebo-controlled | Exclusion criteria: outflow obstruction, use of HRT, urinary tract infection. | | | | Randomization with standard statistical tables with random numbers. Allocation concealment not reported. Baseline data not reported but stated the same in the treatment groups.
RCT to examine effect of oestrogens in treatment of genuine stress incontinence in postmenopausal women | Loss of followup: 6%. | | | | Sample size not justified.
Duration: 3 months
Waetjen, 2004 ^709^ | Multiple Outcomes of Raloxifene trial included women age ≤80 years, >2 years past menopause, who met the World Health Organization criteria for osteoporosis. | | Daily supplements of 400 to 600IU of cholecalciferol and 500mg of calcium raloxifene 60mg/day or raloxifene 120mg/day | Severity of incontinence using the validated Sandvik 4-level index: mild, moderate, severe, and very severe. | No intention to treat Open label.
RCT to examine effects of treatment with raloxifene on urinary incontinence in postmenopausal women. | Exclusion criteria: use of estrogen, progestins, or androgens within 6 months of enrollment, known or suspected cancer, abnormal uterine bleeding, history of thromboembolic disease, and secondary causes of osteoporosis. | | Placebo | “Worsened” - severity score was higher 3 years after baseline, “no change” when there was no change from baseline, and “improved” if the severity score decreased. | Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization.
Duration: 3 years. | Loss of followup: 21% | | | The effect of incontinence on daily activities in 0 (none) to 10(most of the time). The effect of incontinence on feeling with scale from 0 (not at all) to-10 (extremely disturbing) | Sample size justified.
Grady, 2001 ^710^ | 2,763 postmenopausal women < 80 years with coronary disease and intact uteri- from the Heart and Estrogen/Progestin Replacement Study. | | 1 0.625mg/day of conjugated estrogens plus 2.5 mg of medroxyprogesterone acetate in one tablet; 2 Placebo | Self reported severity of incontinence as -improved (decrease of at least 2 episodes/week), -unchanged (change of at most 1 episode/week), -worsened (increase of at least 2 episodes/week) | No Intention to treat. Double blind.
RCT to examine the effects of postmenopausal hormone therapy on severity of urinary incontinence. | The outcomes are reported for 1,525 women who reported at least one episode of incontinence/week at baseline. | | | | Randomization using randomly permuted blocks of size 4 stratified by site. Allocation concealment adequate (reported previously).
Duration of follow up: 4.1 years | Exclusion criteria: average compliance with treatment <80% by pill count | | | | Sample size justified
| Loss of follow up: 21% and 16% in active and placebo groups respectively (excluded from analysis because of bad compliance).

Table F144 Effects local estrogen therapy on progression of urinary incontinence in women

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Von Holst, 2000 ^711^ | 186 hysterectomised women age 40–65 years, with postmenopausal complaints, normal gynecological history and examination, serum estradiol < 30pg/ml and follicle stimulating hormone > 30IU/ml. | 1 7-day-Estradiol patch (1.5mg estradiol/week or 50mg estradiol/24 hours). All patients received active drug therapy (7-days). Estradiol patch) for a further 3 months (three cycles).; 2 Placebo once-weekly | The sum of scores for self-reported incontinence symptoms that occurred since the previous visit. The severity of these symptoms was assessed on a four-point scale (0; no symptoms, 1; mild symptoms; 2; moderate symptoms, 3; severe and heavy symptoms). | Intention to treat.
Placebo controlled | Exclusion criteria: use of sex hormones taken orally within the last 28 days; locally-applied sex hormones within the last 21 days or injectable sex hormones within the last 6 months. | | | Double-blind.
RCT with initial screening phase (phase I), a 3-month placebo-controlled phase (phase II) and a 3-month open followup phase (phase III) to examine the efficacy and tolerability of a continuously applied 7-day-Estradiol patch in the treatment of hysterectomised women with postmenopausal complaints compared with placebo | Loss of followup: one patient did not receive any study medication and 12 patients (5 in active and 7 in placebo group) were excluded from the intention-to-treat analysis of the placebo-controlled phase due to lack of availability of efficacy data | | | Randomization with 1:1 ratio.
Duration: 6 months | | | | Allocation concealment unclear. Baseline data confirmed the adequacy of randomization (no data presented).
| | | | No justification for sample size.
Waetjen, 2005 ^712^ | 417 postmenopausal women age 60–80 years, with a uterus and at least 5 years after menopause, with normal bone mineral density for age (z score not below -2.0 at the lumbar spine). | 1 14mg of transdermal E2 per day.; 2 Placebo. | Self-reported stress Incontinence: leakage “while coughing, sneezing, straining, laughing, or lifting”; and urge incontinence: “an urge to urinate and could not get to the toilet fast enough.” | Intention to treat.
Placebo-controlled | Exclusion criteria: use of estrogen or progestin within 3 months of randomization or having unexplained uterine bleeding, endometrial hyperplasia or an endometrium 5mm or more in double-wall thickness, abnormal mammogram, breast cancer, a history of metabolic bone disease, cancer, coronary disease, cerebrovascular disease, uncontrolled hypertension, uncontrolled thyroid disease, liver disease, fasting triglycerides >300mg/dl, or fasting glucose >180mg/dl. | | Changes in frequency of incontinence from baseline to 4 months and 2 years as “worsened”: episodes increased by 2 or more per week; “unchanged”: frequency changed by no more than 1 episode per week; “improved”: incontinence episodes per week decreased by 2 or more | Double-blind.
RCT to examine effect of ultra low-dose transdermal estradiol (E2) on incontinence in postmenopausal women | Loss of followup: 10%. 83% of the women in active group and 77% in the placebo group continued to use their assigned patch; 84% in both groups used at least 75% of their patches | | | Computer-generated randomization stratified by clinical center in blocks of 4. Treatment numbers were printed on labels adhered to identical-looking study medications.
Duration: 2 years | | | | Allocation concealment adequate. Baseline data confirmed the adequacy of randomization.
| | | | Sample size justified.
Holtedahl, 1998 ^713^ | 95 women, 50–74 years of age with regular incontinence (>2 leakage episodes per month) diagnosed during gynecological examinations, with positive pad test, or self reported in 48 hour chart. | 1 Local estrogen in vagitories or jelly plus physiotherapy and electrostimulation; 2 Delayed treatment | 1 Change in severity of incontinence from start of treatment (index range 0–8).; 2 Change in impact from start of treatment (index range 0–4).; 3 Quantitative measures in relation to micturition.; 4 Criteria based classification; cured, improved, unchanged, worse | No intention to treat.
RCT to examine effects of conservative treatment for urinary incontinence | Exclusion criteria: Cardiac pacemaker, dementia, medical conditions that would prevent following the protocol. | | | Randomization by phone from the university department.
Duration: 6 months for controlled trial | Loss of followup: 3 patients were found protocol deviant and excluded from the analysis. | | | Allocation concealment unclear. Open label. Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Dessole, 2004 ^714^ | 88 postmenopausal women with incontinence confirmed by the direct visualization of loss of urine from the urethra during the standard stress test and by urodynamic investigation. | 1 Intravaginal estriol ovules: 1 ovule/day (1mg) for 2 weeks and then 2 ovules/week for 6 months.; 2 Placebo: vaginal suppositories | Self-reported urinary incontinence complaints as none, mild, moderate, or severe. | Intention to treat.
Placebo-controlled | Exclusion criteria: estrogen treatment, anatomical lesions of the urogenital tract, detrusor over activity and abnormal maximal cystometric capacity; presence of severe systemic disorders, thromboembolic diseases, biliary lithiasis, previous breast or uterine cancer, abnormal uterine bleeding, and body mass index of ≥25kg/ml. | | Cured: change from “mild,” “moderate,” “severe” to “none.” | Double-blind.
RCT to examine the efficacy and safety of intravaginal estriol administration on urinary incontinence, urogenital atrophy, and recurrent urinary tract infections in postmenopausal women. | Loss of followup: 11 women, 4 due to discomfort and 3 due to local adverse reactions | | Improved - change from “moderate” to “mild” or from “severe” to “moderate/mild.” | Randomization was obtained using sets of sequenced, sealed, opaque envelopes, each containing the bottle number to be given to each participant.
Duration: 6 months | | | Urodynamic outcomes: mean maximum urethral pressure, mean maximum urethral closure, mean functional urethral length, and abdominal pressure transmission ratio to the urethra. | Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
| | | Urethrocystometry outcomes.
Zullo, 2005 ^632^ | 59 women with confirmed urodynamic stress incontinence, at least 1 year at menopause status, with serum estradiol <150pmol/l after hysterectomy, without contraindications to local estrogen therapy or to vaginal surgery. | 1 Tension-free vaginal tape procedure plus postoperative vaginal estrogen: 1 estriol ovule/day (1mg) for 1 month, then 2 ovules a week for the 5 months.; 2 Tension-free vaginal tape procedure alone | Self-reported urinary symptoms using standardized questions (International Continence Society definition). | No intention to treat. Single blind (physicians who performed all examinations and urodynamic assessment).
RCT to examine the efficacy of tension-free vaginal tape procedure and topical estrogen therapy on overactive bladder symptoms in menopausal women. | Exclusion criteria: urogenital prolapse above grade 1, detrusor over activity, intrinsic urethral sphincter deficiency, previous urogynecologic surgery, endometrial thickness more than 4mm, previous estrogen therapy within the past 6 months, unexplained uterine bleeding, or history of diabetes mellitus or insipidus, congestive cardiac failure, diuretic therapy, or neoplasms. | | Urodynamic outcomes. | Allocation concealment unclear. Baseline data confirmed adequacy of randomization.
Duration: 6 months | Loss of followup: 3 eligible patients (5%) refused to participate | | | Sample size justified.
Mikkelsen, 1995 ^715^ | 47 postmenopausal women (>1 year after menopause) scheduled for vaginal repair operation for genital descensus, 7 patients with urinary stress incontinence. | 1 Vagifem (25mg/day oestradiol) administered as vaginal pessaries 3 weeks prior to surgery.; 2 Placebo administered daily as vaginal pessaries 3 weeks prior to surgery. | Self perceived satisfaction with the treatment results, presented as cured rate. | No intention to treat.
Placebo-controlled | Exclusion criteria: previous breast and uterine malignancies and other hormone dependent neoplasm, genital bleeding, acute thrombophlebitis. | | | Double blind.
RCT to examine effects of low-dose vaginal treatment with oestradiol before vaginal operation. | Loss of followup: 3 patients preferred conservative treatment, one died, 43 patients included in the analysis. | | | Allocation concealment unclear.
Duration: 3 years | | | | Baseline data not presented.
| | | | Sample size not justified.
Akhila, 2006 ^716^ | 116 menopausal women with self-reported post-menopausal symptoms. | 1 Conjugated equine oral estrogen 0.625mg/day.; 2 Estradiol gel percutaneous 1.25g/day.; 3 Transdermal patch with 50mg/day estradiol | Self reported urinary symptoms of incontinence | No intention to treat. Open label.
RCT to examine the clinical efficacy of oral hormone therapy, percutaneous gel, and transdermal patch in incontinent menopausal women. | Exclusion criteria: contraindications for hormone replacement therapy | | | Allocation concealment unclear. Baseline data confirmed the adequacy of randomization.
Duration: 1 year | Loss of followup: 28 women excluded from the analysis. | | | Sample size not justified.
Lose, 2000 ^717^ | 251 women reporting at least one bothersome lower urinary tract symptom after spontaneous or surgical post menopause. | 1 Oestradiol-releasing ring, 7.5mg oestradiol.; 2 Oestriol pessaries 0.5mg every second day. | Subjective scores of urgency, frequency, nocturia, dysuria, stress incontinence and urge incontinence. | Intention to treat.
RCT to examine the efficacy of an oestradiol-releasing vaginal ring and oestriol pessaries on lower urinary tract symptoms in postmenopausal women. | Exclusion criteria: known or suspected oestrogen-dependent neoplasia or malignancy, vaginal bleeding, clinically significant liver diseases, acute or intermittent porphyria, uterovaginal prolapse II–III, sex hormone treatment within 6 months, vaginal irritation or atrophy or ulceration. | | | Open label. Central randomization.
Duration: 24 weeks | Loss of followup: none | | | Allocation concealment unclear. Baseline data confirmed the adequacy of randomization.
| | | | Sample size justified.
Chompootaweep 1998, ^718^ | 40 postmenopausal women with urogenital symptoms related to estrogen deficiency. | 1 Combined contraceptive intravaginal 1 pill/week at bedtime with 250mg levonorgestrel +30mg ethinyl estradiol.; 2 Intravaginal conjugated estrogen cream (1g=0.625mg conjugated equine estrogens) at bedtime, 3/week in week 1, 2/week in week 2, and then 1/week for the 6 weeks | Self reported urinary urgency | Intention to treat not stated. Open label.
RCT to examine Effects of combined contraceptive intravaginal pill and standard conjugated estrogen cream on urogenital symptoms in postmenopausal Thai women. | Exclusion criteria: thromboembolic disorders, severe liver diseases, estrogen-dependent tumors, high blood pressure (diastolic >140mm/Hg). | | | Randomization procedure not reported. Allocation concealment unclear. Baseline data confirmed the adequacy of randomization.
Duration: 8 weeks | Loss of followup: none. | | | Sample size not justified.
Blom,1995, ^719^ | 19 ambulant elderly women (52 years and older) with confirmed urge incontinence. | 1 Estradiol transdermal therapeutic system (0.05mg estradiol/day).; 2 Estradiol transdermal therapeutic system (0.05mg estradiol/day) combined with naproxen 250mg tablets twice daily.; 3 Placebo matching estradiol transdermal therapeutic system | Bladder-diary charts with frequency of urination, nocturia, and episodes of incontinence. | No intention to treat. Single-blind.
Crossover RCT to examine effects of a transdermal estradiol delivery system, alone and in combination with naproxen, in elderly women with confirmed urge incontinence. | Exclusion criteria: history of breast and endometrial cancer, thromboembolic disorders, severe hypertension, cardiac failure, diabetes mellitus, peptic ulceration. | | Cystometric outcomes | Randomization and allocation concealment not reported. Baseline data not reported.
Duration: 8 weeks, 2 week washout period. | Loss of followup: 15.8% | | | Sample size not justified.

Table F145 Effects of hormone therapy on urinary continence in females (events) (sorted by the rate of continence after the active treatments, from highest to lowest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Akhila, 2006 ^716^ | Estradiol gel percutaneous 1.25g/day | Transdermal patch with 50mg/day estradiol | % cured | 26 | 40 | 90.0 | 100.0 | 0.9 (0.8; 1.0)
N = 116 | Conjugated equine estrogen 0.625mg/day orally | Transdermal patch with 50mg/day estradiol | % cured | 19 | 40 | 40.0 | 100.0 | 0.4 (0.3; 0.6) | 2 (1; 2) | 600 (420; 708)A
Waetjen, 2004 ^709^ | Raloxifene 60mg/day or raloxifene 120mg/day | Placebo | Continence at 3 years | 243 | 125 | 38.2 | 38.5 | 1.0 (0.8; 1.2)
N = 963
Rufford, 2003 ^704^ | 25mg 17 beta-estradiol implant subcutaneous tissue | Placebo implant | Urge incontinence % cured | 7 | 6 | 35.0 | 30.0 | 1.2 (0.5; 2.9)
N = 40
Mikkelsen, 1995 ^715^ | Vagifem (25mg/day oestradiol) administered as vaginal pessaries 3 weeks prior to surgery | Placebo administered as vaginal pessaries daily 3 weeks prior to surgery | Cured rate | 5 | 6 | 25.0 | 33.0 | 0.8 (0.3; 2.1)
N = 47
Kok, 1999 ^698^ | 2mg 17 boestradiol in combination with 2.5, 5, 10 or 15mg dydrogesterone orally once a day. | Changes from baseline. No placebo group | Cured Incontinence (became continent) | 23 | 0 | 23.0 | 0.1 | 47.0 (2.9; 763.5) | 4 (1;528) | 229 (2; 763)E
N = 102
Holtedahl, 1998 ^713^ | Local estrogen in vagitories or jelly plus physiotherapy and electro stimulation | No treatment | Number of cured: no reported leakage and no wet episodes | 8 | 0 | 22.0 | 0.0 | 20.7 (1.2; 346.5)
N = 90
Rufford, 2003 ^704^ | 25mg 17beta-estradiol implant subcutaneous tissue | Placebo implant | Stress incontinence % cured | 4 | 3 | 20.0 | 15.0 | 1.3 (0.3; 5.2)
N = 40 | | | Dysuria, % of cured | 4 | 3 | 20.0 | 15.0 | 1.3 (0.3; 5.2)
| | | Urgency, % of cured | 3 | 2 | 15.0 | 10.0 | 1.5 (0.3; 8.0)
Grady, 2001 ^710^ | 0.625 mg of conjugated estrogens plus 2.5 mg of medroxyprogest erone acetate in one tablet daily | Placebo | No incontinent episodes in the previous week | 109 | 134 | 14.19 | 17.70 | 0.80 (0.64; 1.01)
N = 1,525
100% female
Followup 48 months
Jackson, 1999 ^702^ | Change from baseline after oestradiol valerate 2mg/day | Change from baseline after placebo | % with cured stress incontinence | 5 | 5 | 14.0 | 14.0 | 1.0 (0.3; 3.2)
N = 67

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group;

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F146 Effects of hormone therapy on improvement of urinary incontinence in females (events) (sorted by rate of improvement in continence after active treatment, from the highest to the lowest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Dessole, 2004 ^714^ | Intravaginal estriol ovules: 1 ovule/day (1mg) for 2 weeks and then 2 ovules once weekly for 6 months. | Placebo vaginal suppositories | Rate of cured and improved | 30 | 7 | 68.2 | 16.0 | 4.3 (2.1; 8.7) | 2 (1; 6) | 522 (178; 1233)E
N = 88
Kok, 1999 ^698^ | 2mg 17 boestradiol in combination with 2.5, 5, 10 or 15mg/day dydrogesterone, orally | Changes from baseline. No placebo group | Disappear-acne of Nocturia | 67 | 0 | 65.4 | 0.1 | 135.0 (8.5; 2151.4) | 2 (0; 134) | 653 (7; 2150)E
N = 102
Waetjen, 2004 ^709^ | Raloxifene 60mg/day or raloxifene 120mg/day | Placebo | Improved urinary incontinence at 3 years | 102 | 48 | 27.4 | 25.5 | 1.1 (0.8; 1.5)
N = 963
Ahlstrom, 1990 ^705^ | Estriol 4mg/day and phenylpropanolamine 50mg twice daily | Estriol 4mg once daily | Self-reported improvement in incontinence symptoms | 13 | 11 | 45.0 | 40.0 | 1.2 (0.6; 2.2)
N = 29
Holtedahl, 1998 ^713^ | Local estrogen in vagitories or jelly plus physic-therapy and electro stimulation | No treatment | Number of improved: reduction in frequency amount, or wet episodes | 14 | 4 | 39.0 | 9.0 | 4.3 (1.5; 11.9) | 3 (1;20) | 300 (49; 978)E
N = 90
Grady; 2001 ^710^ | 0.625 mg of conjugated estrogens plus 2.5 mg of medroxypro gesterone acetate in one tablet daily | Placebo 4 months | Improved; decrease of at least 2/week in episodes | 214 | 248 | 27.89* | 32.77 | 0.85 (0.73; 0.99) | 20 (11; 340) | 49 (3; 88)A
N = 1,525 | | Placebo 12 months | Improved; decrease of at least 2/week in episodes | 191 | 236 | 24.89* | 31.17 | 0.80 (0.68; 0.94) | 16 (10; 52) | 63 (19; 100)A
100% female | | Placebo 24 months | Improved; decrease of at least 2/week in episodes | 181 | 222 | 23.55* | 29.36 | 0.80 (0.68; 0.95) | 17 (11; 70) | 58 (14; 94)A
| | Placebo 36 months | Improved; decrease of at least 2/week in episodes | 162 | 203 | 21.08* | 26.84 | 0.79 (0.66; 0.94) | 17 (11; 64) | 58 (16; 92)A
| | Placebo 48 months | Improved; decrease of at least 2/week in episodes | 215 | 241 | 27.96* | 31.87 | 0.88 (0.75; 1.03)
| | Placebo 48 months | Improved or markedly improved | 158 | 194 | 20.57* | 25.66 | 0.80 (0.67; 0.97) | 20 (12; 113) | 51 (9; 85)A
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 2 years | Placebo 2 years | Improved incontinence; the number of incontinence episodes per week decreased by 2 or more | 57 | 80 | 27.4 | 38.2 | 0.7 (0.5; 0.9) | 9 (6; 50) | 108 (20; 175)A
N = 417
Vardy, 2003 ^692^ | Conjugated equine estrogen 0.625mg | Placebo | Pelvic organ prolapse quantization, % of subjects with improved scores | 4 | 0 | 25.0 | 0.1 | 7.9 (0.5; 133.8)
N = 58
Waetjen, 2005 ^712^ | 14mg/day of transdermal E2 for 4 months | Placebo for 4 months | Improved incontinence: the number of incontinence episodes per week decreased by 2 or more | 52 | 74 | 25.0 | 35.2 | 0.7 (0.5; 1.0)
N = 417
Long,2006 ^699^ | Oral 0.625mg of conjugated equine Estrogen/tab let | Topical 0.625mg conjugated equine Estrogen/1g vaginal cream | Bristol Female Lower Urinary Tract Symptoms Questionnaires. improvement in stress urinary incontinence | 8 | 9 | 21.6 | 25.0 | 0.86 (0.38; 1.99)
N = 73
Vardy, 2003 ^692^ | Conjugated equine estrogen 0.625mg; | Placebo | Improvement of urinary symptoms; Average change in angle of deflection | 3 | 0 | 20.0 | 0.0 | 6.1 (0.3; 108.6)
N = 58
Waetjen, 2005 ^712^ | 14mg of transdermal E2 per day for 2 years | Placebo 2 years | Improved stress incontinence: the number of incontinence episodes per week decreased by 2 or more | 37 | 61 | 17.9 | 29.2 | 0.6 (0.4; 0.9) | 9 (6; 27) | 113 (37;168)A
| | | Improved urge incontinence: the number of incontinence episodes per week decreased by 2 or more | 27 | 35 | 13.1 | 16.9 | 0.8 (0.5; 1.2)
Vardy, 2003 ^692^ | Raloxifene 60mg | Placebo | Improvement of urinary symptoms; Average change in angle of deflection | 1 | 0 | 6.7 | 0.0 | 2.6 (0.1; 59.4)
N = 58

Bold- significant differences in outcomes at 95% confidence level;

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F147 Effects of hormone therapy on risk of urinary incontinence in females (events) (sorted by rate of outcome after active treatment, from lowest to highest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Goldstein, 2005 ^691^ | Raloxifene, 150mg/day | Placebo | New or worsening urinary incontinence during the study | 1 | 2 | 0.6 | 1.3 | 0.5 (0.0; 5.3)
N = 619 | | | Newly developed urinary incontinence | 1 | 1 | 0.6 | 0.7 | 1.0 (0.1: 15.3)
| | | New or worsening urinary incontinence during the study | 1 | 2 | 0.7 | 1.3 | 0.5 (0.0; 5.5)
| | | Newly developed urinary incontinence | 1 | 1 | 0.7 | 0.7 | 1.0 (0.1; 15.8)
Warming, 2003 ^693^ | 12 months after discontinuation of levormeloxifene 1.25, 5, 10, or 20mg/day, | Placebo | Urogenital prolapse | 2 | 0 | 1.0 | 0.1 | 1.3 (0.1; 25.9)
N = 301 | Levormeloxifene 1.25, 5, 10, or 20mg/day | Placebo | Urogenital prolapse | 6 | 0 | 3.0 | 0.1 | 3.3 (0.2; 57.3)
Hendrix, 2005 ^695^ | Estrogen plus progestin (E+ P): 0.625mg of CEE plus 2.5mg of medroxyproges ter1 acetate | Placebo | Incident mixed incontinence | 99 | 69 | 3.7 | 2.8 | 1.3 (1.0; 1.8)
N = 5,182 | Estrogen alone: 0.625mg conjugated equine estrogen | Placebo | Incident mixed incontinence | 76 | 50 | 5.0 | 3.2 | 1.5 (1.1 2.2) | 56 (26; 363) | 18 (3; 38)E
Goldstein, 2005 ^691^ | Conjugated equine estrogen 0.625mg/day | Placebo | Newly developed urinary incontinence | 8 | 1 | 5.1 | 0.7 | 7.7 (1.0; 60.8)
N = 619
Long, 2006 ^699^ | Oral 0.625mg of conjugated equine | Topical 0.625mg conjugated equine Estrogen/1 g vaginal cream | Bristol Female Lower Urinary Tract Symptoms Questionnaire -urge urinary incontinence | 2 | 3 | 5.4 | 8.3 | 0.65 (0.12; 3.66)
N = 73 | Estrogen tablet
Jackson, 1999 ^702^ | Post oestradiol valerate 2mg/day | Post placebo | Incontinence with intercourse | 2 | 1 | 7.0 | 3.0 | 2.1 (0.2; 21.7)
N = 67
Goldstein, 2005 ^691^ | Conjugated equine estrogen 0.625mg/day | Placebo | New or worsening urinary incontinence during the study | 11 | 2 | 7.0 | 1.3 | 5.3 (1.2; 23.5) | 18 (3; 400) | 57 (3; 292)E
N = 619
Vestergaard, 2003 ^696^ | Sequential oral oestrogen and progestogen oral continuous oestradiol | No HRT | Incontinence with moderate to severe discomfort (2–4) | 40 | 45 | 8.0 | 9.0 | 0.9 (0.6; 1.3)
N = 1,006
Long, 2006 ^699^ | Oral 0.625mg of conjugated equine Estrogen tablet | Topical 0.625mg conjugated equine Estrogen/1 g vaginal cream | Bristol Female Lower Urinary Tract Symptoms Questionnaire -urinary frequency | 3 | 12 | 8.1 | 33.3 | 0.24 (0.07; 0.79) | 4 (3; 14) | 252 (70; 308)
N = 73
Goldstein, 2002 ^697^ | Levormeloxifene 0.5mg/day | Placebo | Self reported micturition frequency in both active groups | 184 | 39 | 9.0 | 4.0 | 4.7 (3.4; 6.5) | 20 (5; 11) | 50 (94; 221)E
N = 2,924
Hendrix, 2005 ^695^ | Estrogen plus progestin (E + P): 0.625mg CEE plus 2.5mg medroxyproges ter1 acetate | Placebo | Incident urge incontinence | 304 | 272 | 11.4 | 10.0 | 1.0 (0.9; 1.2)
N = 5,182 | Estrogen alone: 0.625mg conjugated equine estrogen | Placebo | Incident urge incontinence | 210 | 184 | 13.8 | 11.9 | 1.2 (1.0; 1.4)
| 0.625mg CEE plus 2.5mg medroxyproges ter1 acetate | Placebo | Incident Stress Urinary Incontinence | 429 | 218 | 16.0 | 8.7 | 1.8 (1.6; 2.2) | 14 (10; 20) | 73 (51; 100)E
Long, 2006 ^699^ | Oral 0.625mg conjugated equine Estrogen/tablet | Topical 0.625mg conjugated equine Estrogen/1 g vaginal cream | Bristol Female Lower Urinary Tract Symptoms Questionnaires stress urinary incontinence | 6 | 13 | 16.2 | 36.1 | 0.45 (0.19; 1.05)
N = 73
Goldstein, 2002 ^697^ | Levormeloxifene 0.5mg/day | Placebo | Self reported Urinary incontinence on both active groups | 338 | 37 | 17.0 | 4.0 | 9.1 (6.5; 12.6) | 8 (2;5) | 130 (221; 463)E
N = 2,924
Hendrix, 2005 ^695^ | Estrogen alone: 0.625mg conjugated equine estrogen | Placebo | Incident Stress Urinary Incontinence | 266 | 131 | 17.4 | 8.5 | 2.1 (1.7; 2.5) | 11 (8;17) | 89 (59; 128)E
N = 3,073
Vestergaard, 2003 ^696^ | Sequential oral oestrogen and progestogen | No HRT | Incontinence with mild discomfort | 100 | 101 | 20.0 | 20.0 | 1.0 (0.8; 1.3)
N = 1,006
Vardy, 2003 ^692^ | Conjugated equine estrogen 0.625mg; | Placebo | Consideration of any indicator of prolapse. | 3 | 2 | 22.0 | 18.0 | 1.3 (0.3; 6.6)
N = 58
Lose, 2000 ^717^ | Oestradiol-releasing ring, 7.5mg oestradiol | Oestriol pessaries 0.5mg every second day | Self reported urgency | 36 | 39 | 27.0 | 33.0 | 0.8 (0.6; 1.2)
N = 251
Long, 2006 ^699^ | Oral 0.625mg of conjugated equine Estrogen tablet | Topical 0.625mg conjugated equine Estrogen/1 g vaginal cream | Bristol Female Lower Urinary Tract Symptoms Questionnaire Nocturia | 10 | 3 | 27.0 | 8.3 | 3.24 (0.97; 10.83)
N = 73
Jackson, 1999 ^702^ | Post oestradiol valerate 2mg/day | Post placebo | Abnormal stream | 10 | 7 | 30.0 | 22.0 | 1.5 (0.6; 3.4)
N = 67
Lose, 2000 ^717^ | Oestradiol-releasing ring, 7.5mg oestradiol | Oestriol pessaries 0.5mg every second day | Self reported Nocturia | 42 | 41 | 31.0 | 35.0 | 0.9 (0.6; 1.3)
N = 251
Dessole, 2004 ^714^ | Intravaginal estriol ovules: 1 ovule (1mg)/day for 2 weeks and then 2 ovules once weekly for 6 months. | Placebo vaginal suppositories | Subjective complaints of stress urinary incontinence. | 14 | 37 | 31.8 | 84.1 | 0.4 (0.2; 0.6) | 2 (2; 3) | 523 (341; 638)A
N = 88
Lose, 2000 ^717^ | Oestradiol-releasing ring, 7.5mg oestradiol | Oestriol pessaries 0.5mg every second day | Self reported urge incontinence | 44 | 0 | 33.0 | | 77.8 (4.8; 1,249.4)
N = 251 | | | Self reported stress incontinence | 46 | 48 | 34.0 | 41.0 | 0.8 (0.6; 1.2)
Waetjen, 2005 ^712^ | 14mg/day of transdermal E2 for 2 years | Placebo 2 years | New developed incontinence at 2 years | 81 | 77 | 39.0 | 36.8 | 1.1 (0.8; 1.4)
N = 417
Steinauer, 2005 ^694^ | Oral conjugated estrogen (0.625mg) and medroxy progesterone acetate (2.5mg) in 1 pill/day | Placebo | New report of weekly urge incontinence | 287 | 220 | 48.0 | 36.0 | 1.3 (1.2; 1.5) | -8 (-17; -5) | -120 (-60; -190)
N = 1,208
Jackson, 1999 ^702^ | Post oestradiol valerate 2mg daily | Post placebo | Intermittent stream | 17 | 20 | 50.0 | 60.0 | 0.9 (0.5; 1.3)
N = 67 | | | Changing outer clothing | 17 | 17 | 53.0 | 50.0 | 1.0 (0.6; 1.7)
Steinauer, 2005 ^694^ | Oral conjugated estrogen (0.625mg) and medroxy progesterone acetate (2.5mg) in 1 pill/day | Placebo | New report of weekly stress incontinence | 322 | 232 | 54.0 | 38.0 | 1.4 (1.3; 1.6) | 6 (4; 10) | 160 (96; 232)E
N = 1,208 | | | New report of weekly incontinence in women, 60 years of age | 57 | 42 | 59.0 | 48.0 | 1.2 (0.9; 1.6)
Vardy, 2003 ^692^ | Tamoxifen 20mg; | Placebo | Consideration of any indicator of prolapse. | 9 | 2 | 60.0 | 18.0 | 3.9 (1.0; 14.9)
N = 58
Jackson, 1999 ^702^ | Post oestradiol valerate 2mg/day | Post placebo | Inability to stop midstream | 20 | 24 | 60.0 | 72.0 | 0.9 (0.6; 1.2)
N = 67
Steinauer, 2005 ^694^ | Oral conjugated estrogen (0.625mg) and medroxy progesterone acetate (2.5mg) in 1 pill/day | Placebo | New report of weekly incontinence | 382 | 302 | 64.0 | 49.0 | 1.3 (1.2; 1.4) | 7 (5;12) | 150 (84; 211)E
N = 1,208
Jackson, 1999 ^702^ | Oestradiol valerate 2mg/day | Placebo | Unexplained incontinence | 24 | 16 | 73.0 | 47.0 | 1.5 (1.0; 2.3) | 4 (2; 95) | 260 (10; 628)E
N = 67 | | | Wearing protection | 24 | 24 | 73.0 | 72.0 | 1.0 (0.8; 1.4)
Vardy, 2003 ^692^ | Raloxifene 60mg | Placebo | Consideration of any indicator of prolapse. | 11 | 2 | 75.0 | 18.0 | 4.8 (1.3; 17.7) | 2 (0; 19) | 570 (51; 3003)E
N = 58
Jackson, 1999 ^702^ | Oestradiol valerate 2mg/day | Placebo | Urinary urgency | 31 | 33 | 93.0 | 97.0 | 1.0 (0.9; 1.1)
N = 67 | | | Stress Incontinence | 33 | 34 | 100.0 | 100.0
| | | Urge Incontinence | 33 | 33 | 100.0 | 97.0 | 1.0 (0.9; 1.1)
Waetjen, 2004 ^709^ | Raloxifene 60mg/day or raloxifene 120mg/day | Placebo | Stress urinary incontinence at 3 years | 99 | 55 | 15.6 | 16.9 | 0.9 (0.7; 1.2)
N = 963 | | | Urge urinary incontinence at 3 years | 164 | 89 | 25.8 | 27.4 | 0.9 (0.8; 1.2)
| | | Mixed urinary incontinence at 3 years | 111 | 47 | 17.5 | 14.5 | 1.2 (0.9; 1.6)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F148 Effects of hormone therapy on progression of urinary incontinence in females (events) (sorted by rate of progression after the active treatment, from lowest to highest)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated 95% CI)
Sample
Goldstein, 2005 ^691^ | Raloxifene, 60mg/day | Placebo | Severity of incontinence: moderate or severe | 0 | 1 | 0.0 | 50.0 | 0.5 (0.0; 7.1)
N = 619 | Raloxifene, 150mg/d | Placebo | Severity of incontinence: moderate or severe | 0 | 1 | 0.0 | 50.0 | 0.5 (0.0; 7.1)
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 4 months | Placebo 4 months | Worsened urge incontinence: the number of incontinence episodes/week increased by 2 or more. | 5 | 21 | 2.4 | 10.2 | 0.2 (0.1; 0.6) | 13 (11; 26) | 78 (39; 93)A
N = 417 | 14mg/day transdermal E2 for 2 years | Placebo 2 years | Worsened stress incontinence: the number of incontinence episodes/week increased by 2 or more. | 20 | 19 | 9.5 | 9.0 | 1.1 (0.6; 1.9)
Holtedahl, 1998 ^713^ | Local estrogen in vagitories or jelly plus physiotherapy and electro stimulation | No treatment | Worse incontinence: self reported worsening of severity or impact | 4 | 13 | 11.0 | 30.0 | 0.4 (0.1; 1.1)
N = 90
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 2 years | Placebo 2 years | Worsened urge incontinence: the number of incontinence episodes/week increased by 2 or more. | 27 | 38 | 13.1 | 18.0 | 0.7 (0.5; 1.1)
N = 417
Vestergaard, 2003 ^696^ | Sequential oral oestrogen and progestogen | No HRT | Frequent voiding: Mild discomfort (1) | 70 | 81 | 14.0 | 16.0 | 0.9 (0.6; 1.2)
N = 1,006
Vardy, 2003 ^692^ | Raloxifene 60mg | Placebo | Increase or worsening in symptoms of incontinence | 2 | 2 | 15.0 | 18.0 | 0.9 (0.1; 5.3)
N = 58
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 2 years | Placebo 2 years | Worsened incontinence: the number of incontinence episodes/week increased by 2 or more. | 35 | 35 | 16.7 | 16.9 | 1.0 (0.7; 1.5)
N = 417
Vardy, 2003 ^692^ | Conjugated equine estrogen 0.625mg | Placebo | Increase or worsening in symptoms of incontinence | 2 | 2 | 18.0 | 18.0 | 0.9 (0.1; 5.3)
N = 58
Vestergaard, 2003 ^696^ | Sequential oral oestrogen and progestogen | No HRT | Frequent voiding: Moderate to severe discomfort (2–4) | 100 | 96 | 20.0 | 19.0 | 1.0 (0.8; 1.3)
N = 1,006
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 4 months | Placebo 4 months | Worsened stress incontinence: the number of incontinence episodes/week increased by 2 or more. | 42 | 28 | 20.2 | 13.6 | 1.5 (1.0; 2.3)
N = 417 | | | Worsened incontinence: the number of incontinence episodes/week increased by 2 or more. | 50 | 40 | 23.8 | 19.3 | 1.3 (0.9; 1.8)
Vardy, 2003 ^692^ | Conjugated equine estrogen 0.625mg | Placebo | Pelvic organ prolapse quantitation, % of subjects with worsened scores | 4 | 2 | 25.0 | 18.0 | 1.7 (0.4; 8.0)
N = 58
Holtedahl, 1998 ^713^ | Local estrogen in vagitories or jelly plus physiotherapy and electro stimulation | No treatment | Unchanged incontinence: no changes in frequency, amount, or wet episodes | 10 | 27 | 28.0 | 61.0 | 0.5 (0.3; 0.8) | 3 (2; 8) | 330 (119; 455; )A
N = 90
Grady, 2001 ^710^ | 0.625 mg of conjugated estrogens plus 2.5 mg of medroxyproge sterone acetate in one tablet daily | Placebo | Worsened-increase of at least 2/ week episodes 4 months | 202 | 166 | 26.35 | 21.91 | 1.20 (1.00; 1.43) | 23 (10, 664) | 44 (1; 95)E
N = 1,525 | | | Worsened-increase of at least 2/ week episodes 12 months | 224 | 180 | 29.18 | 23.80 | 1.23 (1.04; 1.45) | 19 (9; 116) | 54 (9; 108)E
| | | Worsened-increase of at least 2/ week episodes 24 months | 246 | 178 | 32.05 | 23.56 | 1.36 (1.16; 1.61) | 12 (7; 27) | 85 (37; 143)E
| | | Worsened-increase of at least 2/ week episodes 36 months | 256 | 187 | 33.33 | 24.73 | 1.35 (1.15; 1.58) | 12 (7; 27) | 86 (37; 144)E
| | | Worsened-increase of at least 2/ week episodes 48 months | 290 | 212 | 37.8 | 28.02 | 1.35 (1.17; 1.56) | 10 (6; 22) | 98 (46; 157)E
| | | Worsened or markedly worsened 48 months | 293 | 202 | 38.19 | 26.64 | 1.43 (1.23; 1.66) | 9 (6; 16) | 116 (62; 175)E
Vardy, 2003 ^692^ | Tamoxifen 20mg | Placebo | Pelvic organ prolapse quantitation, % of subjects with worsened scores | 5 | 2 | 31.0 | 18.0 | 2.2 (0.5; 9.3)
N = 58 | | | Increase or worsening in symptoms of incontinence | 5 | 2 | 33.0 | 18.0 | 2.2 (0.5; 9.3)
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 4 months | Placebo for 4 months | Unchanged incontinence: the number of incontinence episodes/week increased or decreased no more than 1 | 106 | 95 | 51.2 | 45.5 | 1.1 (0.9; 1.4)
N = 417
Vardy, 2003 ^692^ | Raloxifene 60mg | Placebo | Pelvic organ prolapse quantitation, % of subjects with worsened scores | 10 | 2 | 67.0 | 18.0 | 4.3 (1.2; 16.3) | 2 (0; 36) | 490 (28; 2,752)E
N = 58
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 2 years | Placebo 2 years | Unchanged stress incontinence: the number of incontinence episodes/week increased or decreased no more than 1 | 151 | 129 | 72.6 | 61.8 | 1.2 (1.0; 1.3)
N = 417
Jackson, 1999 ^702^ | Post oestradiol valerate 2mg/day | Post placebo | More than 7 episodes of daytime incontinence | 25 | 23 | 77.0 | 69.0 | 1.1 (0.8; 1.5)
N = 67
Goldstein, 2005 ^691^ | Conjugated equine estrogen 0.625mg/day | Placebo | Severity of incontinence: moderate or severe | 9 | 1 | 81.8 | 50.0 | 1.6 (0.4; 6.7)
N = 619
Waetjen, 2005 ^712^ | 14mg/day transdermal E2 for 4 months | Placebo 4 months | Unchanged urge incontinence: the number of incontinence episodes/week increased or decreased no more than 1 | 178 | 162 | 85.7 | 77.3 | 1.1 (1.0; 1.2) | 12 (182; 6) | 84 (5; 163)E
N = 417
Jackson, 1999 ^702^ | Post oestradiol valerate 2mg/day | Post placebo | More than 7 episodes of nocturnal incontinence | 31 | 28 | 93.0 | 81.0 | 1.1 (1.0; 1.4)
N = 67 | | | Frequency of incontinence episodes (more than never) | 33 | 34 | 100.0 | 100.0
| | | Quantity of lost urine (more than none) | 33 | 34 | 100.0 | 100.0
Waetjen, 2004 ^709^ | Raloxifene 60mg/day or Raloxifene 120mg/day | Placebo | Severe and very severe at 3 years | 29 | 14 | 4.5 | 4.3 | 1.1 (0.6; 2.0)
N = 963 | | | Incontinent episodes <1/month at 3 years | 146 | 67 | 22.9 | 20.6 | 1.1 (0.9; 1.4)
| | | Incontinent episodes/day at 3 years | 57 | 22 | 8.9 | 6.8 | 1.3 (0.8; 2.1)
| | | Wears protection for incontinence at 3 years | 161 | 67 | 41.1 | 33.5 | 1.2 (1.0; 1.6)
| | | Restricts daily activities: sometimes at 3 years | 389 | 198 | 99.2 | 99.0 | 1.0 (0.9; 1.1)
| | | Restricts daily activities: Most of the time at 3 years | 3 | 2 | 0.8 | 1.0 | 0.8 (0.1; 4.6)
| | | Effect on feelings: Somewhat at 3 years | 373 | 191 | 95.2 | 95.5 | 1.0 (0.9; 1.1)
| | | Effect on feelings: Extremely at 3 years | 19 | 9 | 4.8 | 4.5 | 1.1 (0.5; 2.4)
| | | No change in urinary incontinence at 3 years | 218 | 119 | 58.4 | 63.3 | 0.9 (0.8; 1.1)
| | | Worsened urinary incontinence at 3 years | 53 | 21 | 14.2 | 11.2 | 1.3 (0.8; 2.1)

Bold- significant differences in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome inn1 patient = 1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F149 Effects of hormone therapy on perceived urinary incontinence in females (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Baseline (95% CI)
Sample
Cardozo, 1993 ^706^ | 3mg oral oestriol/day | Placebo | Diurnal incontinence, episodes/day | 2.7 ± 3.5 | 1.3 ± 2.3 | 0.5 (0.0; 1.0) | 35.9 (-2.4; 74.2)
N = 64 | | | Nocturnal incontinence, episodes/day | 0.3 ± 0.7 | 0.3 ± 0.8 | 0.0 (-0.5; 0.5) | 0.0 (-163.7; 163.7)
Rufford, 2003 ^704^ | 25mg 17 beta-estradiol implant subcutaneous tissue | Placebo implant | Micturition/24 hours | 8.6 ± 1.4 | 8.0 ± 0.9 | 0.5 (-0.1; 1.1) | 6.4 (-1.5; 14.3)
N = 40
Fantl, 1996 ^701^ | Post conjugated equine estrogens (0.625mg) and medroxyprogesterone (10mg) cyclically | Post placebo | No. of diurnal voluntary micturition//week | 50.0 ± 14.0 | 49.0 ± 15.0 | 0.1 (-0.4; 0.5) | 0.1 (-0.8; 1.1)
N = 83 | | | Number of nocturnal voluntary micturition/week | 9.0 ± 6.0 | 8.0 ± 5.0 | 0.2 (-0.3; 0.7) | 2.3 (-3.7; 8.3)
von Holst, 2000 ^711^ | 7-day-Estradiol patch (1.5mg estradiol/week or 50mg estradiol/24 hour) | Placebo | Change from baseline in Incontinence scores | -1.3 ± 2.0 | -0.8± 1.5 | -0.3 (-0.6; 0.0) | 35.3 (71.4; -0.8)
N = 186
Jackson, 1999 ^702^ | Change from baseline after oestradiol valerate 2mgday | Change from baseline after placebo | Change in median frequency of Nocturia | -0.1 ± 1.3 | 0.1± 0.1 | -0.2 (-0.7; 0.3) | -223.8 (-704.3; 256.7)
N = 67 | | | Change in median in leaks/day | 0.4 ± 0.5 | 0.0 ± 0.4 | 0.9 (0.3; 1.4)
| | | Change in median in pads/day | 0.0± 1.1 | 0.0 ± 0.2 | 0.0 (-0.5; 0.5)
| | | Change in median frequency in micturition/24hour | 0.1 ± 5.6 | -0.6 ± 0.2 | 0.2 (-0.3; 0.7) | -29.7 (50.3; -109.7)
Fantl, 1996 ^701^ | Post conjugated equine estrogens (0.625mg) and medroxyprogesterone (10mg) cyclically | Post placebo | Number of incontinent episodes/week | 10.0 ± 10.0 | 13.0± 14.0 | -0.2 (-0.7; 0.2) | -1.9 (-5.2; 1.5)
N = 83 | Pre conjugated equine estrogens (0.625mg) and medroxyprogesterone (10mg) cyclically | Post placebo | Number of nocturnal voluntary micturition/week | 9.0 ± 6.0 | 8.0 ± 5.0 | 0.2 (-0.3; 0.7) | 2.3 (-3.7; 8.3)
Wilson, 1987 ^708^ | Cyclical treatment with piperazine oestrone sulphate | Placebo | Number of pads changes/day | 1.0 ± 1.9 | 1.7 ± 2.4 | -0.3 (-1.0; 0.3) | -18.9 (-57.6; 19.8)
N = 36 | | | Micturition/day | 8.4 ± 3.0 | 10.4 ± 3.2 | -0.6 (-1.3; 0.0) | -6.1 (-12.6; 0.3)
Fantl, 1996 ^701^ | Pre conjugated equine estrogens (0.625mg) and medroxyprogesterone (10mg) cyclically | Post placebo | Number of incontinent episodes/week | 10.0 ± 10.0 | 13.0 ± 14.0 | -0.2 (-0.7; 0.2) | -1.9 (-5.2; 1.5)
N= =83 | | | No. of diurnal voluntary micturition/week | 50.0 ± 14.0 | 49.0 ± 15.0 | 0.1 (-0.4; 0.5) | 0.1 (-0.8; 1.1)
Vardy, 2003 ^692^ | Tamoxifen 20mg; | Placebo | Improvement of urinary symptoms; Average change in angle of deflection | 0.0 ± 0.0 | -0.5 ± 14.7
N = 58

Bold- significant differences in outcomes at 95% confidence level

Table F150 Effects of hormone therapy on urinary incontinence in females (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | Change % from Control (95% CI)
Sample
Vardy, 2003 ^692^ | Conjugated equine estrogen 0.625mg; | Placebo | Improvement of urinary symptoms; Average change in angle of deflection | 0.0 ± 0.0 | -0.5 ± 14.7
N = 58 | Raloxifene 60mg | Placebo | Improvement of urinary symptoms; Average change in angle of deflection | 0.0 ± 0.0 | -0.5 ± 14.7
Cardozo, 1993 ^706^ | 3mg oral oestriol/day | Placebo | Bladder volume at first desire to void. Ml | 206.0 ± 142.0 | 202.0 ± 114.0 | 0.0 (-0.5; 0.5) | 0.0 (-0.2; 0.3)
N = 64 | | | Detrusor pressure (cm/H2O) | 17.0 ± 15.0 | 22.0 ± 39.0 | -0.2 (-0.7; 0.3) | -0.8 (-3.0; 1.4)
| 3mg oral oestriol/day | Placebo | Cystometric capacity, bladder volume, ml | 333.0 ± 163.0 | 365.0 ± 136.0 | -0.2 (-0.7; 0.3) | -0.1 (-0.2; 0.1)
| | | Cystometric Detrusor pressure (cm/H2O) | 25.0 ± 20.0 | 32.0 ± 65.0 | -0.1 (-0.6; 0.3) | -0.5 (-2.0; 1.1)
Rufford, 2003 ^704^ | 25mg 17 beta-estradiol implant subcutaneous tissue | Placebo implant | First sensation | 200.0 ± 37.5 | 150.0 ± 25.0 | 1.6 (0.9; 2.3) | 1.0 (0.6; 1.5)
N = 40 | 25mg 17 beta-estradiol implant subcutaneous tissue | Placebo implant | Volume P>15cm/H2O | 225.0 ± 87.5 | 250.0 ± 25.0 | -0.4 (-1.0; 0.2) | -0.2 (-0.4; 0.1)
| 25mg 17 beta-estradiol implant subcutaneous tissue | Placebo implant | Maximum capacity | 450.0 ± 13.0 | 320.0 ± 40.0 | 4.4 (3.2; 5.5) | 1.4 (1.0; 1.7)
| 25mg 17 beta-estradiol implant subcutaneous tissue | Placebo implant | Volume voided per micturition | 177.0 ± 16.0 | 161.0 ± 19.5 | 0.9 (0.2; 1.5) | 0.6 (0.2; 1.0)
| 25mg 17 beta-estradiol implant subcutaneous tissue | Placebo implant | Pressure rise of filling | 6.0 ± 5.0 | 10.0 ± 5.0 | -0.8 (-1.4; -0.2) | -8.0 (-14.5; -1.5)
Ahlstrom, 1990 ^705^ | Estriol 4mg/day and phenylpropanolamine 50mg twice daily. | Estriol 4mg/day | Change in functional urethral length, mm | | | 0.5 (-9.0; 10.0)
N = 29 | | | Change in mean maximum urethral closure pressure | | | 1.7 (-13.1; 16.5)
| | | Change in mean maximum urethral pressure | | | 1.5 (-16.4; 19.4)
| Estriol 4mg/day and phenylpropanolamine 50mg twice daily. | Estriol 4mg/day | Leakage during the coughing test | | | -4.2 (-45.4; 37.0)
| Estriol 4mg/day and phenylpropanolamine 50mg twice daily. | Estriol 4mg/day | Residual urine | | | -2.1 (-81.3; 77.1)
| Estriol 4mg/day and phenylpropanolamine 50mg twice daily. | Estriol 4mg/day | Abdominal pressure transmission ratio to the urethra, % | | | -5.1 (-73.7; 63.5)
Dessole, 2004 ^714^ | Intravaginal estriol ovules: 1 ovule (1mg)/day for 2 week and then 2 ovules/week for 6 months. | Placebo vaginal suppositories | Urinary stimulus that cannot be postponed (ml) | 355.7 ± 23.3 | 346.3 ± 23.0 | 0.4 (0.0; 0.8) | 0.1 (0.0; 0.2)
N = 88 | Intravaginal estriol ovules: 1 ovule (1mg)/day for 2 weeks and then 2 ovules/week for 6 months. | Placebo vaginal suppositories | Bladder capacity (ml) | 452.5 ± 47.4 | 429.0 ± 43.2 | 0.5 (0.1; 0.9) | 0.1 (0.0; 0.2)
| | | Bladder compliance (ml/cm/H2O) | 41.1 ± 13.5 | 43.4 ± 13.9 | -0.2 (-0.6; 0.2) | -0.4 (-1.4; 0.6)
| | | maximum bladder pressure, (cm/H2O) | 10.6 ± 2.4 | 11.7 ± 3.1 | -0.4 (-0.8; 0.0) | -3.4 (-7.0; 0.2)
| Intravaginal estriol ovules: 1 ovule (1mg)/day for 2 weeks and then 2 ovules/week for 6 months. | Placebo vaginal suppositories | Maximum urethral closure pressure; (cm/H2O) | 56.9 ± 9.2 | 43.3 ± 6.3 | 1.7 (1.2; 2.2) | 4.0 (2.8; 5.1)
| Intravaginal ovule (1mg)/day for 2 weeks and then 2 ovules/week for 6 months. | Placebo vaginal suppositories | Maximum urethral pressure; (cm/H2O) | 62.2 ± 8.6 | 49.4 ± 6.5 | 1.7 (1.2; 2.2) | 3.4 (2.4; 4.4)
| | | Functional urethral length; (mm) | 28.0 ± 3.1 | 26.6 ± 2.5 | 0.5 (0.1; 0.9) | 1.9 (0.3; 3.5)
| | | Pressure transmission ratio, % | 88.9 ± 9.7 | 70.8 ± 9.0 | 1.9 (1.4; 2.4) | 2.7 (2.0; 3.4)
| | | First stimulus (ml) | 160.3 ± 23.4 | 151.6 ± 15.1 | 0.4 (0.0; 0.9) | 0.3 (0.0; 0.6)
| | | Normal urinary stimulus (ml) | 185.9 ± 22.0 | 172.3 ± 16.6 | 0.7 (0.3; 1.1) | 0.4 (0.2; 0.7)
Jackson, 1999 ^702^ | Change from baseline after oestradiol valerate 2mg/day | Change from baseline after placebo | Maximum voiding flow, ml/second | 1.0 ± 2.7 | 1.0 ± 2.7 | 0.0 (-0.5; 0.5) | 0.0 (-47.9; 47.9)
N = 67 | | | Change in median in average void volume, ml | 21.0 ± 18.7 | -2.0 ± 33.3 | 0.8 (0.3; 1.3) | -42.4 (-17.4; -67.4)
| | | Change in median in functional capacity, ml | 37.0 ± 106.0 | 30.0 ± 66.0 | 0.1 (-0.4; 0.6) | 0.3 (-1.3; 1.9)
| | | Change in median in post-Micturition residual, ml | 0.0 ± 0.0 | 0.0 ± 6.0
| | | Change in median in Detrusor pressure at maximum flow, cm water | 2.0 ± 4.7 | 0.0 ± 4.7 | 0.4 (-0.1; 0.9)
| | | Change in median in maximum urethral closure pressure, cm water | -1.4 ± 9.8 | 1.5 ± 10.7 | -0.3 (-0.8; 0.2) | -18.8 (-50.9; 13.3)
| | | Change in median in functional urethral length, mm | 2.3 ± 5.4 | -0.1 ± 4.6 | 0.5 (0.0; 1.0) | -479.1 (6.9; -965.0)
| Change from baseline after oestradiol valerate 2mg/day | Change from baseline after placebo | Change in median in volume at first desire to micturate | 3.0 ± 78.0 | 19.0 ± 72.0 | -0.2 (-0.7; 0.3) | -1.1 (-3.7; 1.4)
| Change from baseline after oestradiol valerate 2mg/day | Change from baseline after placebo | Change in median in maximum void volume, ml | -10.0 ± 60.0 | -30.0 ± 13.3 | 0.5 (0.0; 0.9) | -1.5 (0.1; -3.2)
Fantl, 1996 ^701^ | Post conjugated equine estrogens (0.625mg) and medroxyprogesterone (10mg) cyclically | Post placebo | Fluid Loss in ml | 101.0 ± 150.0 | 50.0 ± 68.0 | 0.4 (0.0; 0.9) | 0.9 (0.0; 1.8)
N = 83 | Pre conjugated equine estrogens (0.625mg) and medroxyprogesterone (10mg) cyclically | Post placebo | Fluid Loss in ml | 101.0 ± 150.0 | 50.0 ± 68.0 | 0.4 (0.0; 0.9) | 0.9 (0.0; 1.8)
Blom, 1995 ^719^ | Estradiol transdermal therapeutic system (0.05mg estradiol/day) combined with naproxen 250mg tablets twice daily | Placebo | Volume at first desire to void (ml) | 185.6 ± 50.2 | 155.3 ± 46.6 | 0.6 (0.0; 1.3) | 0.4 (0.0; 0.8)
N = 19 | Estradiol transdermal therapeutic system (0.05mg estradiol/day) | Placebo | Maximum bladder capacity (ml) | 318.1 ± 87.8 | 290.3 ± 77.4 | 0.3 (-0.3; 1.0)) | 0.1 (-0.1; 0.3)
| | | Volume at first desire to void (ml) | 171.9 ± 52.7 | 155.3 ± 46.6 | 0.3 (-0.3; 1.0) | 0.2 (-0.2; 0.6)
| Estradiol transdermal therapeutic system (0.05mg estradiol/day) combined with naproxen 250mg tablets twice daily | Placebo | Maximum bladder capacity (ml) | 315.6 ± 74.4 | 290.3 ± 77.4 | 0.3 (-0.3; 1.0) | 0.1 (-0.1; 0.3)
Wilson, 1987 ^708^ | Cyclical treatment with piperazine oestrone sulphate | Placebo | Urine loss (ml/2hours of activity) | 6.0 ± 17.3 | 3.0 ± 15.2 | 0.2 (-0.5; 0.8) | 6.1 (-15.7; 28.0)
N = 36 | | | Maximal urethral closure pressure (cm/H2O) | 53.0 ± 10.8 | 50.0 ± 10.8 | 0.3 (-0.4; 0.9) | 0.6 (-0.8; 1.9)

Bold- significant differences in outcomes at 95% confidence level

Evidence Tables—Clinical Interventions to Reduce Risk of Incidence and Progression of Fecal Incontinence in Adults

Table F151 Clinical interventions on fecal incontinence in long-term care settings

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Effects of conservative management of fecal incontinence in the residents of nursing homes
Schnelle, 1989 ^457^ | 126 incontinent patients from proprietary nursing homes (bed size 90–150), not affiliated with universities with correct discriminatory responses to the instructions to point shown subjects (pencil or glass). | 1 Prompted voiding treatment: check for incontinence, asking for needed toileting assistance, prompted voiding, and socially reinforced for appropriate toileting.; 2 Usual care. | Urinary incontinence measured by nurse as wet checks/total checks and daily percent of appropriate toileting equal the number of times the patient voided in any toilet receptacle/total number of appropriate and incontinent voiding. | No intention to treat. Open label. Randomization and allocation concealment unclear.
RCT to examine the effects of prompted voiding treatment of urinary incontinence in nursing home patients | Exclusion criteria: continence, transfer to hospital during run-in period | | | Baseline data not reported.
Duration: 5–10 days | Loss of followup: 60% during the run-in period, 2.4% after randomization. | | | Sample size not justified.
Ouslander, 2005 ^458^ | 107 patients in the nursing homes, (resided in the facility at least 30 days and not initially admitted for short term care; able to state their name, or in the presence of aphasia, capable of reliably pointing to two objects; required assistance by two or fewer people for transfer from bed to chair; with life expectancy of at least 6 months; not receiving active physical therapy; and ages 60 and older. | 1 Functional Incidental Training: prompted voiding combined with individualized, functionally oriented endurance and strength-training exercises offered 4 times per day, 5 days per week; 2 Usual care. | Urinary and fecal incontinence measured as wet checks/total checks of the participant's every 2 hours. Appropriate toileting rate: number of voids or bowel movements that were continent divided by the total number of voids or bowel movements. Change after the treatments in wet stool checks/total checks 0±22%, p<0.001 | No intention to treat. Open label. Computer-generated random numbers. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
Crossover RCT to examine the effects of functional incidental training on incontinence in nursing homes. | Exclusion criteria: continence, severe behavioral changes, terminally ill.
Duration 8 weeks | Loss of followup: 60%
Schnelle, 200 ^459^ | 256 incontinent residents in 4 nursing homes | 1 Integrated incontinence care and exercise every 2 hours 5 days a week including fluid prompting, prompted toileting, and regular wet checks, arm raise and arm curl exercises.; 2 Usual care. | Fecal and urinary incontinence frequency as % of hourly wet checks and the appropriate toileting ratio calculated by dividing the number of times a resident used a toilet or toilet substitute by the total number of voids. | No intention to treat. Single blind. Computerized randomization. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of integrated incontinence care and exercise on urinary exercise in nursing home residents. | Exclusion criteria: post-acute skilled care units, terminally ill.
Duration 8 months | Loss of followup: 26%
Effects of pharmacological intervention on progression of fecal incontinence in residents of long term care units
Chassagne, 2000 ^720^ | 206 patients older than 65 years, residents of long-term care units, with daily fecal incontinence associated with chronic rectal emptying impairments such as fecal impaction. | 1 Single osmotic laxative -30g lactulose; 2 Osmotic agent 30g lactulose with a rectal stimulant (glycerine suppository) and weekly tap-water enemas | Episodes of fecal incontinence reported by patients and caregivers and associated details of soiled laundry | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of treatment of constipation in elderly patients with fecal incontinence. | Exclusion criteria: severe diarrhea, non compliance (missing treatment of followup for >48 hours), refusal to participate.
Duration: 2 months | Loss of followup: 30.8%
Effects of individualized evidence-based conservative management on fecal incontinence in patients after stroke
Harari, 2004 ^721^ | 146 stroke patients with constipation (<2 bowel movements per week or >2 of the following on more than 1 in 4 occasions: straining, hard stools, feeling of incomplete evacuation), rectal outlet delay (need for self-digitation or feeling of anal blockage or prolonged defecation >10 minutes), and fecal incontinence (any degree of bowel leakage). | 1 RN assessment (history and rectal examination).; 2 Patient care provider education with instructions on regular toilet habits, pelvic floor and sphincter-strengthening exercises, suppository insertion, and laxative and loperamide dose titration.; 3 Evidence based treatment recommendations to patient's general practitioner; 4 Regular care | Self-reported fecal incontinence and bowel movements measured by postal prospective 7-day stool diary. Visual analogue scores for severity rating, quality of life (bowel-related and SF-12). | Intention to treat. Open label.
RCT to examine the effect of evidence based treatment program on fecal incontinence in patients after stroke. | Exclusion criteria: acute diarrhea or colonic disease other than diverticular disease. | | | External computer generated randomization. Allocation concealment not adequate.
Duration of followup: 12 months | Loss of followup: 28% | | | Baseline data confirmed adequacy of randomization.
| | | | Sample size justified.
Effects of dietary interventions on progression of fecal incontinence in adults
Bliss, 2001 ^722^ | 42 adult volunteers with incontinent loose or liquid stools at least weekly. | 1 Usual diet supplemented with 25g of Metamucil, 7.1g of psyllium/day; 2 Usual diet supplemented with 25g of gum arabic/day; 3 Usual diet supplemented with 0.25g of pectin/d as a placebo | Self-reported fecal incontinence: involuntary passage of stool from the rectum. | No intention to treat. Single blind. Allocation concealment unclear. Baseline data reported for age, BMI, and diet. Sample size not justified.
Placebo-controlled | Exclusion criteria: rectal prolapse, colon cancer, or a rectal fistula | | Stool composites
RCT to examine the effects of fiber supplements in community-living adults who were incontinent loose or liquid stools. | Lost of followup: 3 withdrew during the baseline period, 1 subject underwent a hysterectomy; 1 subject required treatment for diverticulitis, and 1 subject had a relapse of clinical depression with suicidal thoughts.
Duration 31 days

Table F151a Effects of clinical interventions on fecal incontinence in community dwelling adults

Study | Participants | Clinical Interventions | Outcomes | Quality Issues
Effects of conservative management programs on postnatal fecal incontinence in females
Glazener, 2001 ^483^ | 747 women with urinary incontinence (defined as any involuntary loss of urine) three months postnatally, living within a 50 km radius and who delivered in these units during a 12 month recruitment period. | 1 Assessment by nurses of fecal incontinence with conservative advice on pelvic floor exercises (8–10 sessions each day of fast and slow contractions with the aim of 80–100 contractions daily) at five, seven, and nine months after delivery supplemented with bladder training if appropriate at seven and nine months.; 2 The control group did not receive any visits from research nurses but received peripartum preparation, which sometimes included pelvic floor exercises, and could seek medical advice. | Self-reported Presence of fecal incontinence: ever lost control of wind or bowel motions from back passage between visits to the toilet | Intention to treat. Single blind. Computer generated randomization stratified by parity (4 versus fewer), method of delivery (caesarean versus other), and frequency of incontinence (at least once a week versus less). Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effect of nurse assessment with reinforcement of pelvic floor muscle training exercises and bladder training among women with persistent postnatal incontinence | Exclusion criteria: mothers of stillborn or dead neonates.
Duration: 12 months | Loss of followup: 25% in active and 35% in the control group.
Glazener, 2005 ^484^ | 747 women with urinary incontinence (defined as any involuntary loss of urine) three months postnatally, living within a 50km radius and who delivered in these units during a 12 month recruitment period. | 1 Assessment by nurses of fecal incontinence with conservative advice on pelvic floor exercises (of 8–10 sessions each day of fast and slow contractions with the aim of 80–100 contractions daily) at five, seven, and nine months after delivery supplemented with bladder training if appropriate at seven and nine months.; 2 The control group did not receive any visits from research nurses but received peripartum preparation, which sometimes included pelvic floor exercises, and could seek medical advice | Self-reported 6 years after intervention presence of fecal incontinence: ever lost control of wind or bowel motions from back passage between visits to the toilet. Reported use of pelvic floor muscle training. | Intention to treat. Single blind. Computer generated randomization stratified by parity (4 versus fewer), method of delivery (caesarean versus other), and frequency of incontinence (at least once a week versus less). Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Adherence to the intervention was the same in active and control group 6 years at followup. Sample size justified.
Glazener, 2001 ^483^ | Exclusion criteria: mothers of stillborn or dead neonates.
6 years followup RCT, 2005 to examine the effect of nurse assessment with reinforcement of pelvic floor muscle training exercises and bladder training among women with persistent postnatal incontinence | Loss of followup: 29% in active and 31% in the control group.
Effects of behavioral interventions on incidence and progression of fecal incontinence in females
Labrecque, 2000 ^482^ | Pregnant women with (n = 493) and without (n = 1,034) previous vaginal birth. | 1 Self administered perineal massage daily from the 34th or 35th week of pregnancy until delivery introducing 1 or 2 fingers 3 to 4 cm deep into the vagina and applying and maintaining pressure; 2 Usual obstetric care | Self-reported fecal incontinence as: never, less than once per week, 1 to 6 times a week, once a day, and more than once a day. | Intention to treat. Single-blind. Central randomization balanced in blocks of 4 or 6 stratified by history of previous vaginal birth, specialty of the attending physician and hospital. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified
RCT to examine the effects of perineal massage performed during pregnancy on perineal symptoms after delivery | Exclusion criteria: high risk of cesarean delivery, including previous cesarean delivery for cephalopelvic disproportion; multiple gestation; placenta previa; severe fetal growth restriction; breech presentation; preeclampsia; nonparticipating physicians; outbreak of genital herpes during the current pregnancy, inability to speak French or English, inability to understand the instructions, and already doing the massage.
Duration of followup: 3 months | Loss of followup: 0.3%
Fynes, 1999 ^723^ | 40 females with impaired fecal continence after obstetric anal sphincter injury. | 1 Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor exercise.; 2 Augmented biofeedback training of pelvic floor with audiovisual feedback and electric stimulation of slow and fast twitch fibers. | Fecal continence questionnaire and anorectal manometry outcomes: mean maximum resting pressure, mean maximum squeeze pressure, squeeze increment, vector symmetry index. | No intention to treat. Single blind. Computer generated randomization. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of augmented biofeedback with sensory biofeedback alone on fecal incontinence and anorectal manometry after obstetric trauma. | Exclusion criteria: not reported
Duration: 12 weeks | Loss of followup: 1 woman
Ilnyckyj, 2005 ^724^ | 23 women over 18 years age with regular and frequent idiopathic fecal incontinence defined as soiling with formed or liquid stool and/or fecal staining or smearing of undergarments for 6 months or more, at least once weekly. | 1 Education and explanation and instruction in pelvic floor muscle strengthening exercises with max possible squeeze duration for 5 repetitions spaced by a 20 second pause, 6 times/day.; 2 Education and visual and verbal biofeedback therapy using a radial catheter with a latex balloon | Self-reported success in bowel control: at least one weekly episode of any degree of incontinence (frank soiling, liquid seepage, staining or smearing) before the trial and no incontinence whatsoever after the trial. | No Intention to treat. Open label. Randomization and allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of biofeedback on fecal incontinence in women. | Exclusion criteria: complicated diabetes, less than 6 months after postvaginal or Caesarean birth, irritable bowel syndrome, inability to attend weekly sessions for 2 months, and conversational insufficient English.
Duration: 2 months | Loss of followup: 22%.
Effects of behavioral interventions on fecal incontinence in adults from the community
Byrne, 2002 ^725^ | 118 patients with neuropathic fecal incontinence. | 1 Pelvic floor exercises and biofeedback; 2 Usual care | Direct questioning of objectives quality-of-life measure on a scale of 0 to 10 reported pre and post treatment. Saint Mark and Pescatori scores of quantitative incontinence were calculated. | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of biofeedback in patients with neuropathic fecal incontinence. | Exclusion criteria not reported
Duration: unclear | Loss of followup: 14.2%
Byrne, 2005 ^726^ | 239 consecutive patients with fecal incontinence diagnosed by a colorectal surgeon with anal manometry and transanal ultrasound, with no improvement after usual conservative treatment including standard dietary advice, use of fiber supplements, constipating medications, and enemas. | 1 Initial face-to-face assessment and treatment with transanal manometry and ultrasound biofeedback, followed by three treatments conducted via telephone and a final face-to-face assessment.; 2 Standard treatment with 5 face-to-face treatment sessions with manometry and ultrasound | St. Mark's Hospital fecal incontinence score (full continence 0; complete incontinence 13). | Intention to treat. Single blind. Nonrandomized trial. Baseline data were comparable. Sample size not justified.
Nonrandomized controlled CT to examine the effects of telephone-assisted biofeedback treatment for patients living in rural and remote areas with the standard face-to-face protocol for patients with fecal incontinence. | Inclusion criteria for telephone-assisted protocol: difficulties attending the clinic regularly, residence in remote areas, spoken English, and access to a telephone. | | Pescatori fecal incontinence score (full continence 0; complete incontinence 6). Anal manometry and external sphincter isometric and isotonic fatigue times.
Duration: 6 months | Exclusion criteria: a complete external sphincter defect, a non functioning stoma, inflammatory bowel disease, acute perianal inflammation, a potentially reversible cause of incontinence (such as diarrhea), or untreated full-thickness rectal prolapse. | | Treatment success: the patient's self-assessed continence ranking (from a Visual Analog Scale), and a composite grading scored by independent colorectal surgeons.
| Loss of followup: 44%
Solomon, 2003 ^727^ | 120 patients with mild to moderate fecal incontinence | 1 Biofeedback with anal manometry; 2 Biofeedback with transanal ultrasound; 3 Pelvic floor exercises with feedback from digital examination alone.; 4 45 minute sections of sphincter exercises with biofeedback (instrumental or digital examination). | St Mark Hospital Fecal incontinence score (0–13), Pescatori fecal incontinence score (0–6), self-reported fecal continence, physiologic sphincter strength, and compliance | No intention to treat. Single blind. Randomization with a chart of random numbers. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of pelvic floor exercises with biofeedback using anal manometry or transanal ultrasound, and pelvic floor exercises with feedback from digital examination alone. | Loss of followup: 15%
Duration: 4 months
Pager, 2002 ^728^ | 83 patients from 120 participants of the RCT with mild to moderate fecal incontinence. | 1 Pelvic floor exercises with feedback from digital examination alone every day or 2–3 times/week.; 2 45 minute sections of sphincter exercises with biofeedback (instrumental or digital examination). | St Mark Hospital Fecal incontinence score (0–13), Pescatori fecal incontinence score (0–6), self-reported fecal continence, physiologic sphincter strength, and compliance | The authors reported followup outcomes from the RCT in subjects who continued treatments. Baseline data confirmed no differences between subjects.
Solomon, 2003 ^727^ | Loss of followup: 31%
Followup evaluation in the participants of the RCT.
Duration of followup: 42 months
Norton, 2003 ^729^ | 171 patients with fecal incontinence. | 1 Standard care with 9 40–60-minute sessions to advise on diet, fluids intake, bowel training.; 2 Standard care with 9 40–60-minute advice sessions on diet, fluids intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day.; 3 Hospital-based computerassisted sphincter pressure biofeedback.; 4 Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes. | Self-reported symptoms of fecal incontinence, fecal continence score, patient's rating of effectiveness of treatment rated as “worse,” “same,” “improved,” or “cured,” and rating of that change on an ordinal scale of -5 to +5. | Intention to treat. Single blind. Randomization with random numbers generated by Excel function. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of biofeedback in patients with fecal incontinence. | Exclusion criteria: previous course of biofeedback or exercises for fecal incontinence, age less than 18 years, major neurologic disease significant cognitive impairment, active inflammatory bowel disease, unable to consider informed consent issues adequately with insufficient written English skills to complete the questionnaires. | | Quality of life (disease specific). Anal manometry outcomes.
Duration: 3 months. | Loss of followup: 29%
Duration of followup: 1 year.
Jorge, 1994 ^730^ | 26 patients with ulcerative colitis after total colectomy with double-stapled ileoanal reservoir. | 1 Pelvic floor exercise program with 10 second contractions for 5 minutes 5 times/day before surgery; 2 Regular care before surgery | Self-reported fecal incontinence score from 0 to 20. Anal manometry outcomes | No Intention to treat. Open label. Randomization and allocation concealment not adequate. Baseline data not reported. Sample size not justified.
RCT to examine the effects of pelvic floor exercise program on fecal incontinence in patients after ileoanal reservoir procedure. | Exclusion criteria: one stage double-stapled ileoanal reservoir without temporary ileostomy.
Duration: 5 weeks. | Loss of followup: none
Miner, 1990 ^731^ | 25 consecutive patients with fecal incontinence. Most patients had idiopathic fecal incontinence associated with abnormal perineal descent and many also had features of the irritable bowel syndrome | 1 Pelvic floor exercise with active sensory retraining (3 20-minute sessions) to perceive small rectal volumes of air into the rectal balloon.; 2 Pelvic floor exercise retraining with no instruction on how to improve performance. | Self-reported fecal incontinence:; - Do you believe your continence has improved?; - Do you now have more warning before an imminent incontinent episode?; - Has your life-style changed?; - Are you able to go out more?; - Can you travel farther from the toilet? Anal manometry outcomes. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed the adequacy of randomization. Sample size not justified.
Crossover RCT to examine the effects of biofeedback training on fecal incontinence.
Duration: 4 weeks
Duration: of followup 1 year.
Effects of electrical stimulation on fecal incontinence in adults
Norton, 2006 ^732^ | 90 patients with fecal incontinence. | 1 Active anal stimulation at 35Hz/ for 40 minutes a day.; 2 Sham anal stimulation at 1Hz. | 1 week bowel diary, symptom questionnaire, manometry, and self-reported patients' evaluation of outcome | Intention-to-treat. Single blind. Computer generated randomization with random numbers. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of anal electric stimulation in the absence of any adjunctive exercises or advice on fecal incontinence | Exclusion criteria: age under 18 years old; pregnancy; vaginal delivery <6 weeks ago; history of pelvic malignancy; active inflammatory bowel disease; active perianal sepsis or painful hemorrhoids or fissure, previous experience of using an electric stimulator to treat urinary or fecal incontinence.
Duration: 8 weeks | Loss of followup: 22.2%
Leroi, 2005 ^733^ | 34 patients with fecal incontinence to solid or liquid stools or urgency episodes causing patients to remain at home to avoid incontinence accidents, with >1/week incontinence episodes for at least 3 months, with demonstrable unilateral bulbo(clitorido)-cavernosus reflex, and who failed other conservative treatments | After permanent implantation of percutaneously placed lead turned ON for 1–3 months, subjects were randomized to: | Self-reported in patient diary number of weekly fecal incontinence and urgency episodes, and mean delay for postponing defecation and manometric outcomes. | No intention to treat. Double-blind. Randomization with a random number table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
Crossover RCT to examine the effects of sacral nerve stimulation on fecal incontinence. | Exclusion criteria: not reported. | 1 Active sacral nerve continuous stimulation with pulse width of 210 microseconds, frequency 14 pulses/second, and amplitude adapted to the patient's perception of perineal and anal sphincter muscle contraction. The stimulator was left on during defecation and urinary voiding.; 2 Sham sacral nerve stimulation with lead turned off.
Duration: 1 month | Loss of followup: 21%
Chang, 2003 ^734^ | 22 patients with functional constipation as defined by Rome II criteria and impaired rectal sensation (rectal desire threshold volume ≥90ml) on an anorectal manometry, not responsive to conventional therapy such as dietary modification or laxatives for at least 6 months. | 1 External electrical stimulation therapy using an anal plug with pulse generator in the anal canal once a day for 20 minutes over 10–12 sessions with pulse width of 360–960 μs, a frequency of 2–110Hz, and an amplitude of 30–35V.; 2 Biofeedback therapy using the EMG system. The visual feedback observing changes in pressure activity on a monitor screen during rise in rectal pressure synchronized with anal relaxation for 60–90 minutes over 10–14 sessions. | Self-reported bowel frequency and habit, degree of straining, sensation of incomplete evacuation, and anal obstruction using visual analogue scale. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of electrical stimulation therapy in constipated patients with impaired rectal sensation. | Exclusion criteria: diabetes mellitus, hypothyroidism, psychiatric disturbances, drug abuse, organic diseases that could lead to constipation. | | Anorectal manometry outcomes
Duration: 10–14 days | Loss of followup: none
Healy, 2006 ^735^ | 58 patients with fecal incontinence female with a mean age of 55 years (range 40–78). | 1 Endo-anal pudendal nerve stimulation daily at home with a portable home unit programmed for frequencies of 3, 10, 20, 30, 40 and 10 Hz and with a current train of 4 s on and 4 s off.; 2 Endo-anal electrical stimulation under physiotherapeutic supervision: | Self reported quality-of-life questionnaire (RAND 36-item general health survey) | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not compared. Sample size not justified
RCT to examine the effects of chronic low-frequency endo-anal electrical stimulation on fecal incontinence. | Exclusion criteria: significant anal sphincter disruption that needed early surgical repair. | 1-weekly treatment of two 15-min cycles of alternate stimulation followed by a patient contraction with EMG biofeedback unit. The first 15-min cycle used 10 Hz followed by a further 15-min cycle of 40 Hz. The second treatment used electrical stimulation alone using the same frequencies 2 times/weekly without biofeedback
Duration 3 months | Loss of follow up: 17%
Effects of electrical stimulation on postpartum fecal incontinence
Mahony, 2004 ^736^ | 60 women with fecal continence 12 weeks after obstetric injury. | Standard Kegel exercises daily:; 1 Standard intra-anal electromyographic biofeedback training of the pelvic floor; 2 Intra-anal electromyographic biofeedback with electrical stimulation of the anal sphincter weekly for 12 weeks by physiotherapists | The structured bowel function questionnaire to report presence of fecal urgency, flatal incontinence, fecal soiling, frank fecal incontinence, and any impact on daily lifestyle scored from 0 (complete continence) to 20 (complete incontinence). | No Intention to treat. Single blind (investigators) Randomization with computer generated allocations in a ratio of 1:1 in sealed opaque envelopes. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to compare intra-anal electromyographic biofeedback alone with intra-anal biofeedback with electrical stimulation of the anal sphincter in treatment of postpartum fecal incontinence. | Exclusion criteria: history of diabetes mellitus, inflammatory bowel disease, irritable bowel disease, previous anorectal surgery, or malignancy. | | Median resting pressure. Median squeeze pressure using anorectal manometry
Duration: 12 weeks | Loss of followup: 6 women did not complete the study and were excluded from the analysis.
Effects of perineal massage in the second stage of labor on fecal incontinence
Stamp, 2001 ^574^ | 1340 women at 36 weeks' gestation expecting normal birth of a singleton progressed in labor to full dilatation of the cervix or 8cm or more if nulliparous or 5cm or more if multiparous. | 1 Massage and stretching of the perineum during the second stage of labor with a water soluble lubricant; 2 Usual Care | Self reported using postal survey urinary and fecal incontinence 3 months after postpartum | Intention to treat. Open label. Stratified by parity status. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine effects of perineal massage in the second stage of labor on urinary and fecal incontinence. | Exclusion criteria: caesarean section and instrumental birth
Duration: 3 months | Loss of follow up:30%
Effects of pharmacological agents on incidence and progression of fecal incontinence in adults
Ho, 2005 ^737^ | 132 patients with chronic anal fissure and symptoms of sharp pain on defecation for more than 6 weeks and/or anal bleeding, together with exposure of internal anal sphincter muscle fibers at the base of the fissure, and the presence of a sentinel pile and/or hypertrophied anal papilla. | 1 ‘Chemical sphincterotomy’ with oral nifedipine 20mg twice a day for 6 weeks.; 2 Lateral sphincterotomy: internal anal sphincter muscle was identified and the muscle proximal to dentate line was lifted with a small pair of artery forceps. The level of internal anal sphincter division was defined accurately before division using diathermy. | Self-reported fecal incontinence, Wexner incontinence scores. | Intention to treat not stated. Open label. Randomization with random numbers table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization Sample size justified.
RCT to examine the effects of lateral sphincterotomy and tailored sphincterotomy on anal incontinence in patients with chronic anal fissure. | Exclusion criteria: previous anal sphincter surgery, pre-existing fecal incontinence, concomitant hemorrhoids who required, inflammatory bowel disease, use of nitrates or calcium channel blockers for hypertension or cardiac conditions. | | Anal manomtery outcomes
Duration of followup: 4 months | Loss of followup: none
De Nardi,2006 ^738^ | 30 consecutive patients with chronic posterior anal fissure defined as symptoms lasting for >3 months and the presence of typical features, such as skin tag, indurations of the edges of the fissure, hypertrophic proximal papilla, and exposure of fibers of internal anal sphincter. | 1 0.2 percent glycerine trinitrate ointment applied three times daily at the anal margin for eight weeks; 2 20 units Botulinum toxin A injection into the internal anal sphincter on each side of the anterior midline | Self-reported fecal incontinence with Wexner incontinence score questionnaire | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of “chemical sphincterotomies” for chronic anal fissure. | Exclusion criteria: acute fissure, low resting tone at digital examination, inflammatory bowel disease, incontinence, previous anal surgery, and treatment with oral or transdermal nitrate.
Duration of followup: 12 months | Loss of followup: none
Ron, 2001 ^739^ | 25 patients older than 18 years with history of constipation and symptoms of outlet obstruction for >1 year, nonrelaxing puborectalis muscle on both modalities, who were unable to expel a rectal balloon and who failed laxatives and enema therapy. | 1 Local injection of Botox—10 units to each side of the puborectalis; 2 Local injection of Botox—20 units to the posterior aspect of this muscle. | Self-reported fecal incontinence | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of botulinum toxin type-A (Botox) injection to the puborectalis muscle in patients with anismus. | Exclusion criteria: concomitant fecal incontinence, pregnancy.
Duration of followup: 52 weeks | Loss of followup: 4%
Mentes, 2003 ^740^ | 111 patients with sever chronic anal fissure with the horizontal fibers of the internal anal sphincter visible in its base. | 1 20 to 30 units (~ 0.3U/kg) of type A botulinum toxin (Botox) injection into the internal anal sphincter. The injection was repeated 2 months later if complete healing was not achieved.; 2 Lateral internal anal sphincterotomy. | Self-reported incidence of anal incontinence using scoring system by Miller (0–18, 18-complete incontinence) | Intention to treat not stated. Single blind. Randomization with random number table. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine effects of lateral internal sphincterotomy and injection of botulinum toxin for the treatment of idiopathic anal fissures. | Exclusion criteria: concurrent fistula, significant haemorrhoidal diseases, inflammatory bowel disease, anal incontinence, slow transit time constipation, diabetes, alcoholism, drug abuse, ano-receptive intercourse, previous anorectal surgery.
Duration of followup: 1 year | Lost of followup: none.
Iswariah, 2005 ^741^ | 38 adult patients older than 18 years with chronic idiopathic fissure in and who had failed conservative treatment. | 1 Botox, 20 units injected on either side of the fissure into the internal anal sphincter.; 2 Sphincterotomy by open or closed technique in the left lateral position using Park's anal retractor | Self reported modified Wexner Fecal Continence scoring system | No Intention to treat. Open label. Randomization suing random numbers tables. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine effects of lateral internal sphincterotomy and injection of botulinum toxin for treatment of idiopathic anal fissures. | Exclusion criteria: prior sphincterotomy or anal dilatation, fissure associated with inflammatory bowel disease, performance of concomitant anal procedure, fecal incontinence, pregnancy or breast-feeding.
Duration of followup: 25 weeks | Loss of followup: 13.6%
Brisinda, 1999 ^742^ | 50 adults with symptomatic chronic posterior anal fissures. | 1 20 units of botulinum toxin injected into the internal anal sphincter on each side of the anterior midline; 2 0.2 percent nitroglycerin ointment applied twice daily | Anal manometry outcomes | Intention to treat not stated. Single blind. Computer-generated random numbers tables. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine effects of botulinum toxin and topical nitroglycerin ointment for treatment of chronic anal fissure. | Exclusion criteria: acute fissure, or fissure associated with other conditions (inflammatory bowel diseases, HIV infection, hemorrhoids, fistula in ano, anal abscesses, or anal or perianal cancer), previous surgical procedures in the anal canal.
Duration of followup: 2 months, 15 months | Lost of followup: none
Siproudhis, 2003 ^743^ | 44 patients 18–75 years old with chronic anal fissure >1 month, mean value of post-defecation anal pain >30mm on a 100mm visual analogue scale 1 week before inclusion. | 1 Single injection of botulinum toxin in the internal anal sphincter, 100 units of Dysport toxin, 250.units/ml. Daily laxatives and suppositories.; 2 Single injection of isotonic saline. Daily laxatives and suppositories | Self-reported incidence of anal incontinence | No Intention to treat. Double-blind. Stratified by center randomization with permuted block =4. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
Placebo-controlled RCT to examine effects of single injection of botulinum toxin in the internal anal sphincter of patients with chronic anal fissure. | Exclusion criteria: anal sepsis, inflammatory bowel disease, cancer, trauma, anal stenosis, previous surgery, functional pelvic disorders, use of non steroidal anti-inflammatory and analgesic drugs.
Duration of followup: 12 weeks. | Loss of followup: 4.5%.
Hallgren,1994 ^744^ | 30 patients operated for ulcerative colitis with endoanal mucosectomy and a hand sewn ileal pouch-anal anastomosis or with abdominal proctocolectomy and stapling of the pouch to the top of the anal canal. | 1 Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days; 2 Placebo with the same frequency. | Self-reported fecal continence. Anal manometry outcomes | No Intention to treat. Double blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
Crossover placebo controlled RCT to examine the effects of Loperamide on fecal continence after restorative proctocolectomy. | Exclusion criteria: not reported.
Duration: 7 days | Loss of followup: 6.6%
Sun, 1997 ^745^ | 11 patients with chronic diarrhea, fecal incontinence >1 time/month, and severe urgency >3 times/week. | 1 Loperamide oxide 4mg twice daily; 2 Placebo | Self-reported fecal incontinence as leakage of several ml of fluid, enough to require cloth change. | Intention to treat. Double blind. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
Placebo controlled crossover RCT to examine the effects of loperamide oxide on anorectal function in patients with chronic diarrhea. | Exclusion criteria: positive microbiologic analysis for feces, fat, and blood, large-volume diarrhea >500ml/day, anal seepage, use of anti diarrhea medication. | | Self-reported fecal urgency as acute desire to defecate which would result in incontinence if not relieved within 30 seconds. Visual analog scale from 0 (absent) to 100 (extreme). Anal manometry outcomes
Duration: 4 weeks with 1 week run-in and wash out | Loss of followup: none
Kneebone, 2004 ^746^ | 338 males receiving definitive radiotherapy for prostate cancer with prescribed dose >60Gy and the superior limit of the treatment fields situated below the level of the greater sciatic notch to ensure that significant portions of small bowel were not irradiated. | 1 3g of oral sucralfate suspension twice daily starting 1 day before RT and continuing every day for 8 weeks; 2 Identical placebo twice daily | Self-reported patients' symptoms of fecal incontinence using the Radiation Therapy Oncology Group Grade 2 or more criteria. | No Intention to treat. Double-blind. Central computer generated randomization a one-to-one stratified allocation within blocks of 8. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
Placebo-controlled RCT to examine the effects of oral sucralfate to prevent fecal incontinence in prostate cancer patients treated with radiotherapy. | Exclusion criteria: active gastro-intestinal conditions including acute diverticulitis, Crohn's disease, or ulcerative colitis, prior colostomy for any reason, significant renal impairment (serum creatinine >0.3 mmol/l). | | Flexible sigmoidoscopy outcomes
Duration: 8 weeks | Loss of followup: 11.8%
Duration of followup: 2 years
Carapeti, 2000 ^747^ | 36 patients with fecal incontinence for solid or liquid stool and ultrasonographically structurally normal anal sphincter muscles. | 1 Topical 10% phenylephrine 0.5 ml applied topically to the anus twice daily for 4 weeks.; 2 Identical placebo gel 0.5 ml applied topically to the anus twice daily for 4 weeks. | Self-reported fecal incontinence score modified from the Wexner scale: 24-worst incontinence; 0-no incontinence scored to analyze the frequency of incontinence for solid or liquid stool or gas, alteration in lifestyle, need to wear a pad, urgency and use of constipating drugs. | No Intention to treat. Double-blind. Central randomization with computer-generated random numbers. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
Placebo controlled crossover RCT to examine the effects of topical phenylephrine in the treatment of faecal incontinence due to internal sphincter dysfunction. | Exclusion criteria: pregnancy, ischemic heart disease, hypertension, aortic aneurysm, treatment with monoamine oxidase inhibitors or tricyclic antidepressants, underlying treatable causes for incontinence such as inflammatory bowel disease or surgically repairable external sphincter.
Duration: 4 weeks, washout 1 week | Loss of followup: not reported
Carapeti, 2000 ^748^ | 12 patients with fecal incontinence, noninflamed pouch for previous ulcerative colitis of normal size and ultrasonographically structurally normal anal sphincter muscles. | 1 Alpha1-adrenergic agonist phenylephrine, topical 10% 0.5ml application 2 times/day; 2 Placebo gel | Self-reported fecal incontinence symptoms (0-no symptoms to 280) and scores using validated Wexner scale from 0-continence to 24 - complete incontinence. | Intention to treat not stated. Double-blind. Computer generated random numbers. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
Placebo controlled crossover RCT to examine the effects of topical phenylephrine gel on fecal incontinence in patients with an ileoanal reservoir pouch. | Exclusion criteria: pregnancy, ischemic heart diseases, hypertension, aortic aneurism, treatment with monoamine oxidase inhibitors or tricyclic antidepressants. | | Anorectal manometry outcomes.
Duration: 4 weeks | Loss of followup: none
Nessim, 1999 ^749^ | 54 patients 23–87 years old after anorectal reconstructive surgery including 32 after sphincteroplasty for fecal incontinence. | 1 Medical bowel confinement: clear liquid diet with loperamide 4mg 3 times/day and codeine phosphate 30mg 4 times/day for 3 days.; 2 Regular diet beginning the day of surgery | Self-reported fecal incontinence scores from 1 to 20 in 32 patients treated with sphincteroplasty for fecal incontinence | No Intention to treat. Single blind. Computer generated randomization. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of medical bowel confinement and regular diet on fecal incontinence after anorectal reconstructive surgery. | Exclusion criteria: age younger than 18 years, immunosupression, prior pelvic irradiation, active proctitis, inflammatory bowel disease
Duration of followup: 13 months | Loss of followup: none
Tankova, 2002 ^750^ | 19 patients with symptomatic chronic anal fissures lasting for >2 months. | 1 Rectal administration of hydrogel containing 0.2% isosorbide-5-mononitrate 2 times/day; 2 Placebo gel. | Self-reported fecal incontinence. Anal manometry outcomes | Intention to treat not stated. Masking not reported but the authors stated that active gel and placebo look the same. Baseline data confirmed the adequacy of randomization. Randomization and allocation concealment not reported. Sample size not justified.
RCT to examine the effects of topical mononitrate hydrogel for the treatment of anal fissure. | Exclusion criteria: Anal fissures associated with other conditions (Crohn's disease, human immunodeficiency virus infection, fistula in ano, anal abscess, anal cancer) and previous surgical procedures.
Duration: 3 weeks. | Loss of followup: none
Duration of followup: 3 months
Effects of surgical interventions on fecal incontinence related to obstetric trauma in females
Fernando, 2006 ^751^ | 64 women with third-degree (3b = greater than 50% external anal sphincter thickness, 3c = internal sphincter injury) or fourth-degree (including anorectal epithelium) perineal tears | 1 End-to-end technique to repair obstetric anal sphincter: torn ends of the external anal sphincter were approximated and repaired with 2–3 mattress sutures using 3-0 PDS sutures.; 2 Overlap technique to repair obstetric anal sphincter: the outer surface of the sphincter was mobilized from the surrounding tissue, the first row of sutures was inserted ~1.5 cm from one side of the torn edge of external anal sphincter and overlapped within 0.5 cm of the other edge of the torn external anal sphincter. | Self-reported fecal incontinence, urgency, flatus incontinence, and improvement of anal incontinence symptoms scored with Wexner scale from; 24 - complete incontinence to 0 - complete continence. | Intention to treat. Single-blind (subjects). Customized computer randomization using minimization protocol. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of primary overlap versus end-to-end repair of the external anal sphincter after acute obstetric trauma. | Exclusion criteria: 3a tear (<50% thickness of the external anal sphincter torn) or a previous 3^rd^ or 4^th^ degree perineal tear. | | Questionnaires were sent at 6 weeks, and 3, 6, and 12 months after the repair
Duration: 12 months | Loss of followup: 19%, 2 women had left the area and could not be contacted, and 10 declined to complete further questionnaires.
Garcia, 2005 ^597^ | 51 women with complete third or fourth degree anal sphincter laceration and who underwent primary repair at the time of vaginal delivery. | 1 End-to-end technique to repair obstetric anal sphincter lacerations: 4 separate sutures of polyglycolic acid to reapproximate the sphincter ends directly.; 2 Overlapping repair of obstetric anal sphincter lacerations used 3 sutures of 2-0 PDS to reapproximate the sphincter ends in an overlapping fashion. | Self-reported urinary and anal incontinence graded with the Fecal Incontinence Score (FIS) from 18 - total incontinence >2/week, scores 1–3 incontinence of flatus only. Anal incontinence was defined as a fecal incontinence score of >0 | No Intention to treat. Single blind. Computer-generated randomization table. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of surgical techniques for the primary repair of obstetric anal sphincter lacerations. | Exclusion criteria: not reported
Duration: 4 months postpartum | Loss of followup: 35.6%
Williams, 2006 ^752^ | 150 women with an anal sphincter injury sustained during childbirth. | 1 End-end repair of the torn anal sphincter with braided polyglactin (Vicryl retains 50% of its strengths at 3weeks, minimal tissue reaction).; 2 Overlap repair of the torn anal sphincter with braided polyglactin (Vicryl retains 50% of its strengths at 3 weeks, minimal tissue reaction).; 3 End-end repair of the torn anal sphincter with PDS (a monofilament suture with minimal absorption until 90 days, no chronic suture sinuses); 4 Overlap repair of the torn anal sphincter with PDS (amonofilament suture with minimal absorption until 90 days, no chronic suture sinuses). | Self-reported fecal incontinence using St Mark's bowel symptom questionnaire and scoring. Anorectal function using endoanal ultrasound. | No Intention to treat. Single blind. Randomization sequence was generated using a table of random numbers in varied blocks of 4–8. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to compare two surgical techniques and two types of suture material for anal sphincter repair after obstetric injury. | Exclusion criteria not reported. | | Anal manometry and pudendal nerve terminal latency tests.
Duration: 3 months | Loss of followup: 20% at 3 months.
Tjandra, 2003 ^753^ | 23 women with localized anterior defect of external anal sphincter after an obstetric trauma, normal pudendal nerve terminal motor latency. | 1 Direct end-to-end repair using 2-0 PDS sutures; 2 Overlapping sphincter repair with fibro muscular ends using 2-0 PDS sutures | Self-reported fecal continence using the Cleveland Clinic Continence Score (0–20); 0 - perfect continence. Endoanal ultrasound, anorectal manometry, and neurophysiologic exam outcomes. | Intention to treat not stated. Single blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of two surgical techniques (direct end-to-end vs. overlapping) of delayed repair of a localized anterior defect of external anal sphincter after an obstetric trauma. | Exclusion criteria: prolonged pudental nerve terminal motor latency.
Duration of followup: 18 months | Loss of followup: none.
Fitzpatrick, 2000 ^754^ | 112 primiparous women who sustained a third-degree tear defined as any recognized disruption of the external anal sphincter (partial or complete). | 1 Primary anal sphincter overlap: the sphincter ends in an overlapping fashion.; 2 Approximation repair: the torn sphincter ends were grasped by means of an Allis forceps and approximated end to end without tension | Self-reported fecal incontinence using detailed bowel function questionnaire scored with a modified Wexner score. anal manometry and anal endosonography outcomes | All subjects included in the analysis. Intention to treat was not stated. Open label. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of primary anal sphincter overlap or approximation repair of third-degree obstetric tears on postpartum incontinence. | Exclusion criteria: not reported.
Duration: 3 months postpartum | Loss of followup: 0%
Effects of clinical interventions to prevent fecal incontinence after obstetric trauma
Dannecke, 2005 ^590^ | 146 primiparous women with an uncomplicated singleton pregnancy >34 weeks of gestation intending a vaginal delivery. | 1 Restrictive episiotomy - avoidance of episiotomy (for fetal indications only).; 2 Liberal - in addition to fetal indications use episiotomy when a tear is judged to be imminent | Self-reported presence of urinary and fecal incontinence with standardized questionnaire. | Intention-to-treat. Open label. Simple random sampling. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
Followup RCT to examine the effects of restrictive use of mediolateral episiotomy vs. routine episiotomy. | Exclusion criteria: previous surgery at the pelvic floor and neurological disorder. | | Anorectal manometry and urodynamic outcomes. Pelvic floor muscle strength with a vaginal palpation. The effort to contract the levator ani was graded with the Oxford Score (4 - strongest).
Duration: 18 months | Loss of followup: 45% in restrictive policy group, 32% in liberal policy group
Sartore, 2004 ^591^ | 519 consecutive primiparous women with singleton pregnancies and spontaneous vaginal delivery with the fetal head in occiput anterior position, residents of Trieste. | 1 Mediolateral episiotomy.; 2 No episiotomy | Stress urinary incontinence - observation of involuntary loss of urine synchronous with coughing (+ stress test) with comfortably full bladder. Selfreported urge incontinence - loss of urine associated with strong desire to void. | No intention to treat. Open label. Groups were comparable at baseline except neonatal weight. Crude odds ratios reported.
Nonrandomized CT to examine the effect of mediolateral episiotomy on puerperal pelvic floor strength and dysfunction. | Exclusion criteria: Not delivered in the lithotomy position, cesarean delivery, third and fourth-degree perineal lacerations, preterm, breech, and operative delivery, anal and urinary incontinence that pre-existed vaginal delivery, and history of vaginal or anal surgery. | | Self-reported anal incontinence - loss of flatus, liquid, or solid stool. Pelvic floor muscle strength scored from 0 to 5.
Duration: 3 months after vaginal delivery | | | Vaginal manometry: abnormal perineometric values <12 cm of water. Urine stream interruption test: abnormal any urine stream interruption test scores >5 seconds.
Hannah, 2002 ^592^ | 1,159 women with singleton live fetus in a frank or complete breech presentation at term (37 weeks' gestation). | 1 Planned vaginal birth group, management was expectant until spontaneous labor began, unless an indication to induce labor (e.g., post term pregnancy); 2 Planned cesarean delivery (e.g., footling breech presentation) scheduled for 38 or more weeks' gestation. If the woman was in labor at the time of randomization, the caesarean section was undertaken as soon as possible. Immediately before caesarean section, the fetal presentation was reassessed and if cephalic, a vaginal birth was planned. | Self-reported stress urinary incontinence and fecal or flatus incontinence within the previous 7 days. | Intention to treat. Open label. Centralized randomization stratified by parity with block sizes of two. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
Term Breech Trial, RCT to examine the effects of planned cesarean section on incontinence 3 months postpartum. | Exclusion criteria: Fetopelvic disproportion, fetus weight >4000g, hyperextension of the fetal head, lethal anomaly or a condition that might cause a mechanical problem at delivery, and contraindication to labor or vaginal delivery. | | Perception of incontinence: no problem at all, a little problem, or a big problem.
Duration: 3 months | Loss of followup: 16.5%
Hannah, 2004 ^593^ | 917 of 1,159 women with singleton live fetus in a frank or complete breech presentation at term (37 weeks' gestation). | 1 Planned vaginal birth group, management was expectant until spontaneous labor began, unless an indication to induce labor (e.g., post term pregnancy); 2 Planned cesarean delivery (e.g., footling breech presentation) scheduled for 38 or more weeks' gestation. If the woman was in labor at the time of randomization, the caesarean section was undertaken as soon as possible. Immediately before caesarean section, the fetal presentation was reassessed and if cephalic, a vaginal birth was planned. | Self-reported stress urinary incontinence and fecal or flatus incontinence within the previous over the previous 3 to 6 months. Perception of incontinence: no problem at all, a little problem, or a big problem. | Intention to treat. Open label. Centralized randomization stratified by parity with block sizes of two. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
Followup the Term Breech Trial, RCT to examine the effects of planned cesarean section on incontinence 2 years postpartum. | Exclusion criteria: Fetopelvic disproportion, fetus weight >4,000g, hyperextension of the fetal head, lethal anomaly or a condition that might cause a mechanical problem at delivery, and contraindication to labor or vaginal delivery.
Duration: 2 years | Loss of followup: 20.9% in planned Cesarean groups and 19.6% in vaginal birth group.
Fitzpatrick, 2002 ^755^ | 178 primiparae in either spontaneous or induced labor with a singleton fetus, cephalic presentation between 37 and 42 weeks of gestation with effective epidural analgesia in situ. | 1 Immediate pushing; 2 60-minute delay, prior to the commencement of active pushing. If delivery was not imminent after 60 minutes pushing, a decision was made regarding the need for instrumental or caesarean delivery. | Self-reported FI using bowel function questionnaire With modified continence score from 0 - complete continence, to 20 - complete incontinence. | All patients were analyzed, Intention to treat not stated. Single blind. Computer-generated randomization, ratio of 1:1 in blocks of 10. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of delayed vs. immediate pushing in second stage of labor with epidural analgesia on postpartum faecal continence. | Exclusion criteria: diabetes, irritable bowel syndrome or other bowel or neurological disorder | | Anal manometry outcomes. Anal ultrasound to evaluate potential structural damage to the anal sphincters.
Duration: 3 months | Loss of followup: none
Johanson, 1999 ^596^ | 607 women requiring assisted vaginal delivery. | 1 Delivery with vacuum extractor.; 2 Forceps delivery. | Self-reported fecal and urinary incontinence 5 years postpartum | No intention to treat. Open label. Randomization procedure is not described. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
Followup RCT to examine the effects of delivery by forceps or vacuum extractor on maternal and child outcomes. | Exclusion criteria: 47% of participants form the original RCT were not contacted for unclear reasons.
Duration: 5 years postpartum. | Loss of followup: 26.2% non responders to the survey 5 years postpartum.
Fitzpatrick, 2003 ^756^ | 130 primiparous women in either spontaneous or induced labor with a singleton fetus, cephalic presentation, between 37 and 42 weeks of gestation and required instrumental assistance with delivery. | 1 Vacuum assisted delivery; 2 Low-cavity, non-rotational forceps assisted delivery | Self-reported fecal continence scored from 0 - complete continence, to 20 - complete incontinence. Fecal urgency - unable to defer defecation for >5 minutes. Anal manometry outcomes. | Intention to treat. Open label. Computer-generated randomization, ratio of 1:1 in balanced blocks of 10. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of forceps or vacuum assisted vaginal delivery on anal sphincter function in standardized management of labor. | Exclusion criteria: diabetes, irritable bowel syndrome or other bowel or neurological disorders | | Endoanal ultrasound outcomes.
Duration: 12 weeks | Loss of followup: 16 failed vacuum-forceps
Sultan, 1999 ^757^ | 44 from 313 contacted participants in Keele University Multicenter Assisted Delivery Trial (607 women were randomized in the original trial) | 1 Delivery with vacuum extractor; 2 Forceps delivery. | Anal endosonography outcomes. Anal manometry outcomes. | Intention to treat. Single blind. Randomization procedure is not described. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effect of forceps and vacuum delivery on anal sphincter trauma 5 years postpartum. | Exclusion criteria: unclear why only 313 from 607 participants were contacted for a survey; 44 only agree to have anal endosonography and manometry 5 years postpartum.
Duration: 5 years postpartum
Effects of surgical interventions to reduce fecal incontinence in females
Faltin, 2005 ^758^ | 752 nulliparous women older than 18 years with no scheduled cesarean delivery with second-degree perineal tear (spontaneous or after episiotomy). | 1 Clinical and ultrasound examination of the anal sphincter immediately after vaginal delivery; 2 Clinical examination alone | Self-reported fecal incontinence, need to wear a pad, and lifestyle alterations caused by fecal incontinence using the Wexner scale grading (0-absent; 4- daily). | Intention-to treat. Single blind. Computer-generated randomization in blocks (4, 6, and 8) arranged in random order. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine whether diagnosis of sphincter tears followed by immediate surgical repair reduces the occurrence of incontinence. | Exclusion criteria: anal sphincter ruptures (third- or fourth-degree perineal tear, International Classification of Diseases, 10th Revision), Cesarean delivery, intact perineum or minimal perineal tear ruptures (first-degree perineal tear).
Duration: 3 months and 1 year | Loss of followup: 0.8%
Deen, 1994 ^759^ | 20 elderly female patients with full-thickness rectal prolapse and fecal incontinence. | 1 Abdominal resection rectopexy and pelvic floor repair; 2 Perineal rectosigmoidectomy and pelvic floor repair. | Self-reported fecal incontinence graded from A (fully continent) to D. anal manometry outcomes. | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed the adequacy of randomization. Sample size not justified.
RCT to examine the effects of abdominal resection rectopexy or perineal rectosigmoidectomy and pelvic floor repair in elderly female patients with full-thickness rectal prolapse and faecal incontinence. | Exclusion criteria: not reported.
Duration of followup: 17 months | Loss of followup: none
Sayfan, 1990 ^760^ | 29 women with full-thickness rectal prolapse. | 1 Marlex mesh posterior rectopexy alone.; 2 Sigmoidectomy combined with a sutured posterior rectopexy | Self-reported fecal incontinence, anal manomtery outcomes and rectal emptying during proctography. | Intention to treat not stated. Open label. Not randomization. Baseline data not reported. Sample size not justified.
Non randomized controlled CT to examine the effects of sutured posterior abdominal rectopexy with sigmoidectomy or Marlex rectopexy on fecal incontinence in patients with rectal prolapse. | Exclusion criteria: not reported.
Duration of followup: 2 weeks | Loss of followup: none.
Yoshioka, 1999 ^761^ | 24 women with post obstetric neuropathic fecal incontinence. | 1 Gluteus maximus transposition (without electrical stimulation).; 2 Total pelvic floor postanal repair with anterior levatoroplasty | 20 point clinical incontinence score. | Intention-to-treat. Open label. Permuted block randomization. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of total pelvic floor repair with gluteus maximus transposition for women with post obstetric fecal incontinence. | Exclusion criteria: comorbidity (diabetes), endosonographic sphincter defect, previous anal surgery. | | - failing to achieve full continence; - fecal urgency secondary outcome measures:; - post-operative complications; - adverse functional effects; - physiological outcomes
Duration of followup: 18 months | Loss of followup: not reported
Deen, 1993 ^762^ | 36 women 28–75 years with neuropathic fecal incontinence confirmed by manometry with >4 incontinent episodes/month. | 1 Total pelvic floor repair; 2 Anterior levatorplasty and sphincter plication alone; 3 Postanal repair alone; 4 Control: 18 females undergoing herniorrhaphy and cholecystectomy | Self-reported fecal continence. | No Intention to treat. Open label. Computer generated random tables. Allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine total pelvic floor repair with anterior levatorplasty and sphincter plication alone and postanal repair alone. | Exclusion criteria: isolated anal sphincter defect, diabetes mellitus. | | Manometric and radiologic outcomes.
Duration: 6 months | Loss of followup:53%
Davis, 2004 ^763^ | 38 females with fecal incontinence who failed other conservative treatments, with persistent leakage of liquid or solid stool over at least the previous 12 months, with external anal sphincter defect identifiable on endoanal ultrasound. | 1 Anterior overlapping sphincter repair using interrupted nonabsorbable sutures and levatorplasty using absorbable sutures.; 2 Anterior overlapping sphincter repair plus visual or auditory biofeedback with dual-balloon pressure system during pelvic floor exercise 2 times/day. Three types of exercises: ‘maximal’ -maximal squeeze for as long as possible up to 10 seconds; ‘submaximal’ - halfway squeeze held for up to 5 seconds; or series of repetitive fast squeeze and relax contractions. | Self-reported fecal incontinence symptoms with 3-point scale of ‘improved,’ ‘remained the same,’ or ‘got worse,’ change in continence score ranging from 0 to 20 (0 - no incontinence to 20 - complete incontinence), and anorectal outcomes. | Intention to treat. Single blind. Randomization with computer generated list of random numbers. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of adjuvant biofeedback following anal sphincter repair on fecal incontinence. | Exclusion criteria: Coexistent rectocele, full thickness rectal prolapse, congenital abnormalities, non-obstetric trauma to the sphincter complex, inflammatory bowel disease or significant, women under the age of 18 years, planning pregnancy or who suspected pregnancy.
Duration of biofeedback: 6 weeks | Loss of followup: 5.3%
Duration of followup: 3 months and 1 year
Deen, 1995 ^764^ | 33 women with neuropathic fecal incontinence with a history of prolonged or difficult vaginal delivery, >6 fecal accidents/month, using pad for fecal incontinence. | 1 Adjuvant internal anal sphincter plication in pelvic floor repair; 2 Pelvic floor repair alone | Self-reported fecal incontinence scores from 1 - satisfactory to 7 - poor. Anorectal manometry outcomes | Intention to treat not stated. Open label. Randomization with random number tables. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of adjuvant internal anal sphincter plication in women with neuropathic fecal incontinence. | Exclusion criteria: external sphincter defect, diabetes mellitus, rectal prolapse.
Duration of followup: 1 year. | Loss of followup: none
Davis, 2004 ^763^ | 47 consecutive female patients with defect of external anal sphincter identifiable on endoanal ultrasound and fecal incontinence who failed to control symptoms of persistent leakage of liquid or solid stool over at least the previous 12 months. | 1 Direct sphincter repair and levatorplasty with pelvic floor muscle exercise training with maximal or submaximal squeeze for 10 seconds 10 times day in different positions. Biofeedback therapy 3 months after surgery using dual-balloon pressure system with color led visual or auditory signals of sphincter pressure as feedback.; 2 Direct sphincter repair and levatorplasty | Self-reported fecal continence using fecal incontinence scale with continence score (0 - no incontinence to 20 - complete incontinence). | No Intention to treat. Open label. Randomization with computer generated list of random numbers. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of adjuvant biofeedback following sphincter surgery. | Exclusion criteria: coexistent rectocele, full thickness rectal prolapse, congenital abnormalities, non-obstetric trauma to the sphincter complex, inflammatory bowel disease or significant neuropathy, women under the age of 18 years, planning pregnancy or who suspected pregnancy. | | Endoanal ultrasonography outcomes.
Duration of followup: 12 months | Loss of followup:18%
Van Tets, 1998 ^765^ | Type D incontinence (no control of solid stool by Parks and Browning). | 1 Postanal repair with levator ani and plicated of the external anal sphincter.; 2 Total pelvic floor repair with a combination of postanal repair, anterior Ievatorptasty, and anterior sphincter plication | Self-reported fecal incontinence | Intention to treat not stated. Open label. Randomization by drawing lots. Allocation concealment not reported. Baseline data confirmed the adequacy of randomization. Sample size not justified.
RCT to examine the effects of postanal and total pelvic floor repair for female neurogenic incontinence. | Exclusion criteria: sphincter defects.
Duration of followup: 12 weeks | Loss of follow up: not reported
Thakar, 2002 ^599^ | 279 women referred for hysterectomy because of benign disease; most of the women were premenopausal. | 1 Subtotal hysterectomy; 2 Total hysterectomy | Self-reported urinary incontinence using standardized Questionnaire. Stress incontinence scored from 0 - none to 4 - always. Twin-channel subtracted cystometrography and uroflowmetry outcomes. | No intention to treat for cystometry outcomes. Double blind. Randomization with computer-generated numbers. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of total abdominal hysterectomy and subtotal abdominal hysterectomy performed for benign uterine diseases. | Exclusion criteria: age >60 years, suspected cancer, a body weight that exceeded 100kg, previous pelvic surgery, known endometriosis, abnormal cervical smears, symptomatic uterine prolapse, and symptomatic urinary incontinence for which the patient might seek expert medical advice.
Duration: 1 year | Loss of followup: 16% in total and 12% in subtotal abdominal hysterectomy groups.
Peeters, 2006 ^766^ | 641 patients with localized adenocarcinoma of the prostate. | 1 Three-dimensional conformal radiotherapy 68Gy; 2 Three-dimensional conformal radiotherapy 78Gy | Fecal incontinence as use of incontinence pads for rectal loss of blood, mucus, or stools (requiring the use of pads more than twice a week) reported using Radiation Therapy Oncology Group/European Organization for the Research and Treatment of Cancer questionnaire. | No Intention to treat. Open label. Randomization stratified by hospital, hormonal therapy, age, and four treatment groups. Allocation concealment not reported. Baseline data did not confirm adequacy of randomization. Sample size not justified
RCT to examine the effects of three-dimensional conformal radiotherapy for prostate cancer. | Exclusion criteria: not reported
Duration of followup: 44 months | Loss of followup: 0.6%.
Fransson, 2001 ^686^ | 166 patients with localized prostate carcinoma cytologically or histologically verified as T1a–T2, G1–G2, pN0, and M0. | 1 Radiotherapy with a total dose of 4.8Gy (range, 62.3–70.0Gy) given for 5 days a week, 2 grays (Gy) per fraction.; 2 Active surveillance | Self-reported urinary and fecal incontinence using validated symptom specific self assessment questionnaire, QUFW94 with values between 0 and 10; 0 - “no problem/very good function” and 10 - “many problems/very bad function.” | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of radiotherapy for localized prostate carcinoma. | Exclusion criteria: expected survival <10 years.
Duration of followup: 30–40 months | Loss of followup: 35%.
Little, 2003 ^676^ | 301 patients: 3 with histologically confirmed adenocarcinoma of the prostate and no metastatic disease treated with a four-field box technique to a dose of 46Gy. | 1 Radiation with a four-field box technique to a dose of 70Gy arm; 2 Radiation with three-dimensional conformal techniques to generate a sixfield boost plan of a total dose of 78Gy | Self-reported bladder, bowel and sexual function (Fowler) | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
Followup RCT to examine the effects of radiotherapy for prostate cancer on urinary incontinence and bowel function. | Exclusion criteria: not reported
Duration of followup: 3 years | Response rate 70%.
Effects of bowel management in patients with spinal cord injury and symptoms of neurogenic bowel dysfunction
Christensen, 2006 ^767^ | 87 patients 18 years or older after spinal cord injury at any level at least 3 months after injury and at least one of the following symptoms of neurogenic bowel dysfunction: 1) spending >30 minutes attempting to defecate each day or every second day, 2) episodes of fecal incontinence >1 per month, 3) symptoms reflecting autonomic dysreflexia before or during defecation, and 4) abdominal discomfort before or during defecation. | 1 Transanal irrigation with integrated system of coated rectal balloon catheter, control unit including a manual pump, and a water container with the volume increased to 1,500ml or reduced gradually to 250ml.; 2 Conservative bowel management with scheduled bowel care at least every 2 days, modulated diet, fluids, and regular physical activity and use of laxatives or constipating medicine. | Cleveland Clinic constipation scoring system (0–30, 30 = severe symptoms). St Mark's fecal incontinence grading system (0–24, 24 = severe symptoms) Neurogenic Bowel Dysfunction Score (0-no symptoms, 47 = severe symptoms). | Intention to treat. Open label. Computer-generated block-randomized across centers. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of transanal irrigation on fecal incontinence in patients with spinal cord injuries. | Exclusion criteria: coexisting major unsolved physical problems due to the injury, performance of transanal irrigation on a regular basis, evidence of bowel obstruction or inflammatory bowel disease, history of cerebral palsy or cerebral apoplexy, multiple sclerosis, diabetic polyneuropathy, previous abdominal or perineal surgery (excluding minor surgery such as appendectomy or hemorrhoidectomy), pregnancy or lactation, evidence of spinal shock, mental instability, treatment with more than 5mg/day prednisolone, and implant for sacral nerve stimulation. | | The modified American Society of Colorectal Surgeon fecal incontinence scores (0–4, 4 = high quality of life)
Duration: 10 weeks | Loss of followup: 6.8%
Effects of surgical interventions on fecal incontinences in adults with hemorrhoid disease
Hetzer, 2002 ^768^ | 40 patients with second- and third-degree hemorrhoid disease. | 1 Stapled hemorrhoidectomy (Longo technique) with circular anal dilatator introduced to reduce the prolapse of the anoderm and parts of the anal mucous membrane.; 2 Excision hemorrhoidectomy (Ferguson technique). | Self-reported fecal incontinence | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of stapled hemorrhoidectomy and excision hemorrhoidectomy on fecal incontinence. | Exclusion criteria: not reported
Duration of followup: 12 months | Loss of followup: none
Konsten, 2000 ^769^ | 138 patients with second-degree and thirddegree hemorrhoids. | 1 Hemorrhoidectomy with no retractor (Miller method).; 2 Hemorrhoidectomy with forced anal dilation and after treatment for 6 months (original Lord's procedure.; 3 Hemorrhoidectomy with forced anal dilation. | Self-reported fecal incontinence | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of anal dilation and hemorrhoidectomy for haemorrhoidal disease on fecal incontinence. | Exclusion criteria: not reported
Duration of followup: 1 year. | Loss of followup: 14%, 14 patients died.
Jayne, 2002 ^770^ | 40 patients with grade III or IV hemorrhoids.
RCT to examine the effects of open diathermy haemorrhoidectomy and a new technique of haemorrhoidectomy using the Ligasure device suited to day-case surgery on fecal incontinence. | Exclusion criteria: use of regular anticoagulants, immunosuppressant or analgesics, American Society of Anesthesiologists grade III and IV risk, pregnancy, and the inability to give written informed consent. | 1 Ligasure haemorrhoidectomy applying repeated diathermy forceps across the hemorrhoid with associated skin tag. Completion of coagulation was signaled by the feedback sensors, and haemorrhoidal tissue was excised along the line of coagulum.; 2 Open diathermy haemorrhoidectomy | Self-reported fecal incontinence. | No Intention to treat. Single blind. Randomization with a random numbers table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
Duration of followup: 3 months | Loss of followup: none
Galizia, 2000 ^771^ | 48 consecutive patients with severe prolapsed piles suitable for surgical haemorrhoidectomy. | 1 Complete excision of three hemorrhoids (Milligan-Morgan technique) and lateral internal sphincterotomy up to the dentate line, in left haemorrhoidectomy wound.; 2 Complete excision of three hemorrhoids (Milligan-Morgan technique) | Self-reported fecal incontinence. Anal manometry outcomes. | No Intention to treat. Open label. Randomization using random number table. Allocation concealment not adequate. Baseline data not reported. Sample size not justified.
RCT to examine the effects of adding a lateral internal sphincterotomy to haemorrhoidectomy | Exclusion criteria: younger than 30 years or over 50 years, associated anorectal diseases such as anal scars, fissures, fistulas in ano, proctitis, or thrombosed hemorrhoids.
Duration of followup: 24 months | Loss of followup: none.
Lawes, 2004 ^772^ | 34 patients with prolapsing hemorrhoids. | 1 Ligasure haemorrhoidectomy with controlled quantity of bipolar diathermy current to tissue ensuring the complete coagulation of blood vessels; 2 Standard diathermy haemorrhoidectomy | Self-reported fecal incontinence using validated continence scoring system, the Continence Grading Scale | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
Followup RCT to examine the effects of Ligasure haemorrhoidectom y on fecal incontinence in patients with prolapsing hemorrhoids. | Exclusion criteria: not reported
Duration of followup: 12months | Loss of followup: 11.7%.
Filingeri, 2004 ^773^ | 102 patients with fourth-degree hemorrhoids. | 1 Submucosal hemorrhoidectomy with radiofrequency bistoury.; 2 Conventional Parks' hemorrhoidectomy | Self-reported fecal continence | No Intention to treat. Double blind. Randomization using random number table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of submucosal hemorrhoidectomy with radiofrequency bistoury or conventional Parks' haemorrhoidectom y on fecal incontinence. | Exclusion criteria: presence of previous proctologic surgery or associated proctologic diseases, pregnancy, scores III or IV on the ASA score of the American Society of Anesthesiologists.
Duration of followup: 6 months | Loss of followup: 7.8%
Johannsson, 2006 ^774^ | 225 patients older than 18 years attended the clinic for haemorrhoidectomy. | 1 Open (Milligan-Morgan) haemorrhoidectomy; 2 Closed (Ferguson) haemorrhoidectomy with wounds sutures without tension | Self-reported anal incontinence using validated questions and an Miller incontinence scores | No Intention to treat. Open label. Randomization stratified by the center. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of open (Milligan-Morgan) and closed (Ferguson) haemorrhoidectomy on fecal incontinence. | Exclusion criteria: history of anal incontinence.
Duration of followup: 1 year | Loss of followup: 6.2%
Khan, 2001 ^775^ | 30 patients with Grade 2 and 3 symptomatic hemorrhoids. | 1 Excisional Hemorrhoidectomy with the ultrasonically activated scalpel (Harmonic Scalpel).; 2 Closed excisional hemorrhoidectomy assisted by electrocautery | Self-reported fecal incontinence, and quality of life using the Short Form-36 survey | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified
RCT to examine the effects of closed excisional hemorrhoidectomy and the Harmonic Scalpel technique on fecal incontinence. | Exclusion criteria: not reported
Duration of followup: 6 weeks | Loss of followup: not reported
van Tets, 1997 ^776^ | 40 patients with symptomatic third-degree hemorrhoids with normal continence. | 1 Closed hemorrhoidectomy performed intra-anally using the Parks' anal retractor; 2 Closed hemorrhoidectomy performed perineally without the use of a retractor | Anal manometry outcomes. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine effects of the Parks' anal retractor on anal sphincter function during closed hemorrhoidectomy | Exclusion criteria: not reported.
Duration of followup: 12 weeks | Loss of followup: none.
Ho, 2000 ^777^ | 119 consecutive patients with prolapsed irreducible hemorrhoids. | 1 Conventional open diathermy hemorrhoidectomy.; 2 Stapled hemorrhoidectomy | Self-reported fecal incontinence and quality of life outcomes. Anal manometry outcomes. | Intention to treat not stated. Single blind. Randomization by drawing sealed envelopes. Allocation concealment not adequate. Baseline data confirmed the adequacy of randomization. Sample size not justified.
RCT to examine effects of stapled or conventional open diathermy hemorrhoidectomy on fecal incontinence in adults. | Exclusion criteria: previous perianal surgery, acute thrombosis of internal hemorrhoids, bleeding disorders. | | Endoanal ultrasound outcomes.
Duration of followup: 3 months | Loss of followup: not reported
Effects of the clinical interventions in patients with rectal diseases to reduce risk of fecal incontinence
Schouten, 1991 ^778^ | 70 patients with anorectal abscess. | 1 Incision, drainage and fistulectomy with primary partial internal sphincterotomy.; 2 Incision and drainage alone with secondary partial internal sphincterectomy | Self-reported anal continence | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of fistulectomy in patients with anorectal abscess. | Exclusion criteria: recurrent abscess.
Duration of followup: 42 months | Loss of followup: 5.7%
Singer, 2005 ^779^ | Patients with fistula-in-ano for at least 3 months. | 1 Tisseel-VH fibrin sealant intra-adhesive cefoxitin 100mg.; 2 Tisseel-VH fibrin sealant surgical closure of primary opening.; 3 Tisseel-VH fibrin sealant intra-adhesive cefoxitin 100mg surgical closure of primary opening | Self-reported fecal incontinence. | No Intention to treat. Open label. Randomization with random numbers table. Allocation concealment adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of Tisseel-VH fibrin sealant in combination with intra-adhesive cefoxitin, surgical closure of primary opening, or both modifications on fecal incontinence in patients with chronic fistula-ano. | Exclusion criteria: not reported.
Duration of followup: 12 months | Loss of followup: none
Libertiny, 2002 ^780^ | 70 patients with chronic anal fissure for >2 months, with the presence of ulcerated induration, and the presence of internal sphincter fibers at the base of the fissure, who failed to respond to treatment with stool softeners and topical ointments. | 1 Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day for 8 weeks.; 2 Lateral sphincterotomy | Self-reported fecal incontinence. | Not intention to treat. Open label. Randomization by selection of sealed postcards. Allocation concealment not reported. Baseline data not reported. Sample size justified
RCT to examine the effects of glyceryl trinitrate or lateral sphincterotomy on fecal incontinence in patients with chronic anal fissure. | Exclusion criteria: acute fissures, postpartum stage, incontinence, previous history of anorectal surgery
Duration of followup: 24 months | Loss of followup: not reported
Mishra, 2005 ^781^ | 40 consecutive patients with primary idiopathic chronic anal fissure with symptoms (pain, bleeding) lasting for more than 6 weeks, fibers of internal anal sphincter visible at the floor of the fissure, sentinel pile, and induration of the edges. | 1 Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day; 2 Lateral sphincterotomy | Self-reported fecal incontinence | No intention to treat. Open label. Randomization using randomized block design (balance by age, sex, and weight). Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified
RCT to examine the effects of glyceryl trinitrate or lateral sphincterotomy on FI in patients with for chronic anal fissure. | Exclusion criteria: secondary fissures, systemic diseases (diabetes mellitus, jaundice, collagen diseases), pregnancy, or those being treated with nitrates.
Duration of followup: 6 weeks | Loss of followup: not reported
Oettle, 1997 ^782^ | 24 consecutive patients with chronic anal fissure. | 1 Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day.; 2 Lateral sphincterotomy | Self-reported fecal incontinence | Intention to treat. Open label. Randomization with random number tables (odd-even). Allocation concealment not reported. Baseline data not reported. Sample size justified
RCT to examine the effects of glyceryl trinitrate or lateral sphincterotomy on FI in patients with chronic anal fissure. | Exclusion criteria: Crohn's disease, tuberculosis, AIDS, anal abscess or fistula.
Duration of followup: 22 months | Loss of followup: 0%
Richard, 2000 ^783^ | 90 patients with symptomatic chronic anal fissures (fibrosis at the base of fissure, visible internal sphincter, hypertrophied anal papilla proximal to fissure, sentinel pile distal to fissure). | 1 Application of 0.25% nitroglycerin twice per day to perianal area 3 times/day; 2 Internal sphincterotomy | Self-reported fecal incontinence using Continence Index by Jorge and Wexner. | No Intention to treat. Open label. Central computer generated randomization with permuted blocks of 2, 4, and 6 stratified by center. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified
RCT to examine the effects of topical nitroglycerin or internal sphincterotomy on fecal incontinence in patients with chronic anal fissure. | Exclusion criteria: refusals of Internal sphincterotomy, healing of fissure before surgery, fissure was not observed at surgery, sepsis, Crohn's disease, AIDS, practicing anal intercourse, contraindication to nitrates.
Duration of followup: 6 months | Loss of followup: 8.8%
Evans, 2001 ^784^ | 65 patients with symptoms of chronic anal fissure (symptoms >2 weeks). | 1 Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day for 8 weeks.; 2 Lateral sphincterotomy | Self-reported minor fecal incontinence. | No intention to treat. Open label. Central randomization. Allocation concealment not adequate. Baseline data not reported. Sample size justified
RCT to examine the effects of glyceryl trinitrate or lateral sphincterotomy on fecal incontinence in patients with chronic anal fissure. | Exclusion criteria: inflammatory bowel disease, AIDS, previous fecal incontinence, sphincter injury or surgery, medical conditions that contraindicated general anesthesia, use of nitrates.
Duration 8 weeks. | Loss of followup:7.7 %
Duration of followup:12 months
Zimmerman, 2003 ^785^ | 30 patients with perianal fistula. | 1 Parks retractor during fistula repair.; 2 Scott retractor during fistula repair. | Self-reported fecal continence using Rockwood fecal continence Severity Index. Anal manometry outcomes. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization Sample size not justified.
RCT to examine the effects of two different types of anal retractors on fecal continence after fistula repair. | Exclusion criteria: fistulotomy.
Duration of followup: 12 weeks | Loss of followup: none.
Ho, 2005 ^786^ | 20 patients with fistula-in-ano confirmed by endoanal ultrasound. | 1 Dermal island flap anoplasty with cutaneous advancement flap into the rectum; 2 Conventional treatment: lay open fistulotomy or seton insertion | Self-reported fecal incontinence scores. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization Sample size not justified.
RCT to examine the effects of dermal island flap anoplasty on fecal incontinence in patients with transsphincteric fistulain-ano. | Exclusion criteria: not reported.
Duration of followup: 16 weeks | Loss of followup: none.
Clinical interventions in patients with rectal cancer
Peeters, 2005 ^674^ | 1,861 patients with histologically confirmed adenocarcinoma of the rectum with inferior margin of the tumor had <15 cm from the anal verge and below the level of S1 and S2. | 1 Radiotherapy with total dose of 25Gy administered in 5 fractions over 5 to 7 days before total mesorectal excision.; 2 Total mesorectal excision | Self-reported urinary and fecal incontinence with 4-point scale from “no, never” to “sometimes” (<1/week), “often” (>1/ week but not every day), and “yes, always” (every day) for timedependent symptoms and from “no, not at all” to “a little,” “pretty much,” and “very seriously” for timeindependent symptoms. | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of preoperative short-term radiotherapy in patients treated with total mesorectal excision. | Exclusion criteria: distant metastases, fixed tumors, locally treated (transanal resected) tumors
Duration of followup: 5 years | Loss of followup: 32%, 597responded to questionnaire.
Dahlberg, 1998 ^787^ | 400 patients younger than 80 years with respectable rectal cancer participated in nationwide Swedish Rectal Cancer Trial. 171 patients survived after a minimum of five year responded to the questionnaire. | 1 Preoperative high-dose radiotherapy with 25Gy given in 5 fractions for 5–7 days followed by anterior resection of rectal cancer.; 2 Anterior resection of rectal cancer alone | Self-reported defecation frequency, emptying difficulties, urgency, and incontinence | No Intention to treat. Open label. Randomization and allocation concealment not reported in this article. Baseline data confirmed adequacy of randomization. Sample size justified.
Followup RCT to examine effects of preoperative high-dose radiotherapy on long-term bowel function in patients with rectal cancer. | Exclusion criteria: postoperative stomas and dementia.
Duration of followup: 5 years | Loss of followup: 57% from the initial trial, 16% among survivors.
Pollack, 2006 ^675^ | 1,406 patients with biopsy-proven adenocarcinoma of the rectum, resectable for cure by an abdominal procedure who participated in the Stockholm I and II trials. | 1 Abdominal rectal resection with preoperative radiotherapy in a dose of 25 (5 × 5) Gy using a two field technique (The Stockholm I trial) or four-field box technique (The Stockholm I trial II).; 2 Abdominal rectal resection without preoperative radiotherapy | Self reported fecal and urinary incontinence using the European Organization for Research and Treatment of Cancer (EORTC) Quality of Life Questionnaire (QLQ) | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data did not confirm adequacy of randomization. Sample size not justified
RCT to examine the effects of rectal cancer surgery with or without preoperative radiotherapy on incontinence. | 252 alive 15 years after surgery surveyed Exclusion criteria: distant metastases, locally advanced cancer or previous irradiation to the pelvis, local excision; mental or physical condition that did not allow to participate in the survey. | | | From the original publication: Balanced central randomization lists with a block size of six - 596 were randomized to radiotherapy
Duration of followup:15 years | Loss of follow up: 90% (139 patients available for follow-up and willing to participate).
Allgayer, 2005 ^788^ | 90 patients with colorectal cancer, lower anterior resection as the standard surgical procedure; a UICC II/III tumor stage; macroscopically and histologically tumor-free resection margins; normal laboratory tests including carcinoembryonic antigen (CEA) and a normal abdominal ultrasound/CT on admission. | 1 Intensive daily pelvic floor exercise under the supervision of therapist (30–40 minutes) for 3 weeks in routine rehabilitation programs with biofeedback intra-anal electromyogram electrode device. Postoperative irradiation (total dose 50.4 ±/2.0 Gy) applied in split doses (1.8Gy, 5//week).; 2 Intensive daily pelvic floor exercise under the supervision of therapist (30–40 minutes) for 3 weeks in routine rehabilitation programs With biofeedback intra-anal electromyogram electrode device. | Self-reported severity of fecal incontinence using Modified Cleveland Incontinence Score (MCIS) questionnaire 16-point scale: <6.0 total incontinence with complete inability to retain solid stools; 7.0–12.0- partial incontinence with incontinence for liquid stools; and >14.0 almost normal continence. The major criteria included stool frequency (number of daily evacuations), stool consistence, urgency (time to reach a toilet in minutes, seconds or immediately), discrimination between air, liquid and/or solid stool, spoiling to underwear and concomitant antidiarrheal medication and/or bulk-forming agents. Each item graded from 0 to 3 by the patient and by a trained nurse/ physician and subsequently controlled by an independent observer. | No intention to treat. Open label. Not randomized with significant differences at baseline. No adjustment reported.
Controlled CT to examine the effects of pelvic floor exercise/ biofeedback training combined with irradiation on fecal incontinence after surgery for colorectal cancer. | Exclusion criteria: impaired general health conditions (Karnofsky index <80), age >75 years, a second malignancy or other relevant adverse clinical conditions such as advanced heart failure (NYHA III/IV), pulmonary diseases, metabolic diseases, poorly controlled diabetes (Hba1c >/7.7%), neurologic diseases and/or language barriers.
Duration of followup: 3 weeks and one year. | Loss of followup: 34.7%
Lundby, 2005 ^789^ 15933797 | 494 patients with Dukes B or C rectal carcinoma who were surveyed 15–20 years after surgery. | 1 Postoperative radiotherapy after anterior resection.; 2 Anterior resection alone | Self-reported fecal incontinence. | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed the adequacy of randomization. Sample size not justified.
RCT to examine the effects of adjuvant postoperative radiotherapy for rectal cancer on fecal incontinence. | Exclusion criteria: not reported
Duration of followup: 15–20 years | Loss of follow up:81%
Effects of the surgical interventions on fecal incontinence in patients with rectal prolapse
Luukkonen, 1992 ^790^ | 30 consecutive patients with a full-thickness circumferential rectal prolapse. | 1 Posterior sutured abdominal rectopexy combined with sigmoidectomy complete rectal prolapse and end-to-end anastomosis made with a circular stapler.; 2 Polyglycolic acid mesh rectopexy without sigmoidectomy for complete rectal prolapse anterior rectal wall free | Self-reported anal continence graded from 0 to 3: normal (grade 0), incontinent for flatus (grade 1), incontinent for liquid stool (grade 2), incontinent for solid stool (grade 3). Anal manometry outcomes | No intention to treat. Open label. Randomization with random numbers tables. Allocation concealment not adequate. Baseline data not reported. Sample size not justified.
RCT to examine effects of abdominal rectopexy and sigmoid resection with polyglycolic acid mesh rectopexy without sigmoidectomy for complete rectal prolapse. | Exclusion criteria: not reported.
Duration of followup: 6 months | Loss of followup: 3.3%
Racalbuto, 2004 ^791^ | 100 patients with 3rd and 4th degree hemorrhoids. | 1 Stapled prolapsectomy using longo circular stapler.; 2 Traditional Milligan-Morgan Hemorrhoidectomy with exeresis of the haemorrhoidal piles upon low ligature of each vascular pedicle | Self-reported fecal incontinence using Continence Grading Scale with Wexner scores. Anal manomtery outcomes. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of haemorrhoidal stapler prolapsectomy or Milligan-Morgan hemorrhoidectomy on fecal incontinence. | Exclusion criteria: thrombosed hemorrhoids, partial prolapse (only one nodule), perianal fistulas, presence of chronic associated fissures.
Duration of followup: 48 months | Loss of followup: not reported
Novell, 1994 ^792^ | 63 patients with full thickness rectal prolapse and coexistent fecal incontinence. | 1 Ivalon sponge with sutured rectangle of sponge placed along the length of the sacrum.; 2 Sutured rectopexy with sutured rectangle of sponge or sutures alone placed along the length of the sacrum | Self reported fecal incontinence as fecal soiling or using a pad | No intention to treat. Open label. Randomization with random numbers tables. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of Ivalon sponge versus sutured rectopexy for full-thickness rectal prolapse. | Exclusion criteria: not reported.
Duration of followup: 47 months | Loss of followup: 12 died from causes unrelated to surgery - 19%
Solomon, 2002 ^793^ | 40 patients with full thickness rectal prolapse with or without fecal incontinence. | 1 Laparoscopic rectopexy; 2 Open abdominal rectopexy | Self-reported fecal incontinence scores with visual analog scale | No intention to treat. Single blind. Randomization not reported. Allocation concealment unclear. Baseline data confirmed adequacy of randomization. Sample size justified
RCT to examine effects of laparoscopic and open abdominal rectopexy in patients with full thickness rectal prolapse. | Exclusion criteria: concomitant gynecological procedures, previous rectopexy, large irreducible prolapse.
Duration of followup: 24 months | Loss of followup: 2.5%
Galili, 1997 ^794^ | 37 consecutive patients with complete rectal prolapse. | 1 Posterior abdominal rectopexy with non-absorbable mesh (Polypropylene, Prolene, Ethicon Ltd).; 2 Posterior abdominal rectopexy with absorbable mesh (Polyglycolic acid, Dexon, Davis & Geck) | Self-reported impact on quality of life in scale from 0 to 10. Social activity as 0 - inability to leave home; 1- unrestricted social life. Fecal incontinence as 0 -complete incontinence, 0.5 - incontinence for loose stool only, 1 - complete continence. | Intention-to-treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of polyglycolic acid and polypropylene mesh for rectopexy in the treatment of rectal prolapse. | Exclusion criteria: not reported.
Duration of followup: 3.6 years | Loss of followup: none
Boccasanta, 2006 ^795^ | 40 patients (55 females; mean age, 70.9 ± 11.3 years) with full thickness rectal prolapse, rectal procidentia >5cm; fecal incontinence with score >10. | 1 Altemeier's procedure with levatorplasty, monopolar electrocautery and hand sewn anastomosis.; 2 Altemeier's procedure with levatorplasty using harmonic scalpel and circular stapler | Self-reported fecal continence using a validated scoring system (Wexner score, ranging from 0 - full continence to 20 - complete incontinence). Anal manometry and electromyogram outcomes. | Intention to treat not stated. Single blind. Computer-generated randomization list, with block size 4–6. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of Altemeier's procedure with levatorplasty with handwritten and stapled anastomosis in patients with full thickness rectal prolapse and fecal incontinence. | Exclusion criteria: associated colorectal diseases including cancer, rectal procidentia <5cm; fecal incontinence score <10; absolute contraindications to surgery; mental disorders; inflammatory bowel disease; polyps.
Duration of followup: 28 months | Loss of followup: none
Boccasanta, 1998 ^796^ | 21 patients with complete full thickness rectal prolapse with variable degree of fecal incontinence aged between 22–76 years. | 1 Laparoscopic stapled Well's rectopexy, perineal physiotherapy, external electric stimulation, and perineal biofeedback.; 2 Well's rectopexy by the open technique without division of lateral rectal ligaments, perineal physiotherapy, external electric stimulation, and perineal biofeedback | Self-reported fecal incontinence scores from 0 - complete continence to 6 - complete incontinence. | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of laparoscopic rectopexy and open technique in the treatment of complete rectal prolapse. | Exclusion criteria: not reported. | | Dynamic defecography, anorectal manometry, and anal electromyography outcomes.
Duration of followup: 25.7 – 29.5 months. | Loss of followup: none.
Effects of the surgical interventions on anal sphincter to prevent incidence and progression of fecal incontinence in adults
Wiley, 2004 ^797^ | 79 patients with chronic idiopathic fissure-inano (defined as fissure-in-ano with >6 weeks symptom duration) in whom conservative treatment had failed, suitable for lateral sphincterotomy. | 1 Closed lateral internal sphincterotomy (Hoffman and Goligher) using a short stab incision and blind division of the internal sphincter guided by the surgeon finger.; 2 Open lateral sphincterotomy (Parks) via a 1cm radial incision with division of the internal sphincter under direct vision. | Self-reported fecal incontinence with standardized questionnaires (modified Wexner score): score range of 0 to 20, 0 - complete or normal continence | No intention to treat. Open label. Central randomization. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization Sample size justified.
RCT to examine the effects of open and closed internal sphincterotomy on fecal incontinence in patients with chronic anal fissure. | Exclusion criteria: previous sphincterotomy or anal dilation, fissure associated with inflammatory bowel disease, suspicion of malignant fissure or ulcer, concomitant procedure (i.e., hemorrhoidectomy) to be performed at the time of sphincterotomy (excision of skin tags was permitted), and anesthetic requirements, which included spinal or caudal blockade.
Duration of followup: 52 weeks | Loss of followup: 3.7%
Parellada, 2004 ^798^ | 63 patients with chronic anal fissure (anal pain at defecation for at least 2 months) on proctologic examination with observation of sphincter fibers at the base of the fissure independent of the presence of the sentinel pile or hypertrophic papilla who failed conservative treatments with a high-fiber diet, bulking agents, and warm sit baths. | 1 Surgical: open lateral internal spincterotomy and mucose closure with chromic catgut.; 2 Chemical: local 0.2% isosorbide dinitrate - pea-size quantity applied manually at the entrance of the anus, 3 times/day immediately after a warm sit bath, for 6 weeks. | Self-reported fecal incontinence. Anal manometry outcomes. | No intention to treat. Open label. Randomization with random numbers: odd for the treatment group and even for the control group. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of lateral internal sphincterotomy with local 0.2% isosorbide dinitrate on fecal incontinence in patients with chronic anal fissure. | Exclusion criteria: not reported.
Duration of followup: 24 months | Loss of followup: 14%
Wong, 2002 ^799^ | 112 patients older than 18 year, with a fecal incontinence for >6 months and score of 88 or greater (scale, 1–120), who failed surgical treatment, with life expectancy >2 years. | Implantation of Acticon trade mark artificial bowel sphincter - solid silicone elastomer device. | Self-reported fecal incontinence using Fecal Incontinence Scoring System (FISS), from 0 - complete continence to 120 - complete incontinence. | Not randomized not controlled trial. The authors reported outcomes before and after the treatment.
Not randomized not controlled multicenter trial to examine the effects of Acticon trade mark artificial bowel sphincter for fecal incontinence. | Exclusion criteria: adverse comorbities, fecal incontinence scores <88, Crohn's disease, irritable bowel syndrome as only cause of fecal incontinence, active pelvic sepsis, pregnancy, history of pelvic radiation, anal receptive intercourse.
Duration of followup: 12 months | Loss of followup: 2.6%
Arroyo, 2005 ^800^ | 80 patients with chronic anal fissure (presence of fibrous induration or exposed internal sphincter fibers) after at least 6 weeks of conservative treatments. | 1 Close lateral internal sphincterotomy; 2 Chemical sphincterotomy with 25 units botulinum toxin injected into the internal sphincter | Self-reported fecal incontinence using the Cleveland Clinic Scoring System (0 - perfect continence to 20 - complete incontinence) | Intention to treat not stated. Computer generated randomization. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of close lateral internal sphincterotomy and botulinum toxin sphincterotomy for chronic anal fissure. | Exclusion criteria: associated anal diseases (stenosis, abscess, fistula, hemorrhoids), comorbidities (inflammatory bowel disease, AIDS, tuberculosis, sexually transmitted diseases), anticoagulants, and pregnancy.
Duration of followup: 2 months and 1– 3 years | Loss of followup: none
Zbar, 2003 ^801^ | 34 patients with cryptogenic high transsphincteric fistulas. | 1 Modified cutting seton, which repaired the internal anal sphincter muscle and re-routed the seton through the intersphincteric space.; 2 Conventional cutting seton | Self-reported fecal continence using Pescatori's continence Scale. Anal manometry outcomes. | Intention to treat not stated. Open label. Randomization with random numbers. Allocation concealment not reported. Baseline data confirmed the adequacy of randomization. Sample size not justified.
RCT to examine the effects of conventional cutting vs. internal anal sphincterpreserving seton for high trans-sphincteric fistula. | Exclusion criteria: not reported.
Duration of followup: 12–13 months | Loss of followup: none.
Osterberg, 2004 ^802^ | 70 patients with disabling fecal incontinence of idiopathic (neurogenic) origin, persistent after dietary advice and a standardized treatment with bulking agents attempted for at least 2 months. | 1 Anterior levatorplasty with mobilization of external sphincter.; 2 Anal (and vaginal in women) plug electrostimulation of the pelvic floor with stimulation frequency was 25Hz and the duration 1.5 seconds, with a pulse-train interval of 3 seconds. | Self-reported anal incontinence, pad use, stool frequency using standard bowel questionnaire to calculate Miller's incontinence score (0 - total continence to 18 - maximum incontinence). | No intention to treat. Open label. Permuted block (4) randomization stratified by baseline squeeze and resting pressure. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of levatorplasty and anal plug electrostimulation of the pelvic floor in idiopathic faecal incontinence. | Exclusion criteria: endosonographic anal sphincter defect, rectal prolapse or intra-anal intussusception, previous anorectal surgery other than haemorrhoidectomy. | | Anorectal manometry outcomes.
Duration of followup: 12 months | Loss of followup: 15.7%
Tjandra, 2004 ^803^ | 82 patients (64 females; median age, 66 years) with severe fecal incontinence and a low anal resting pressure caused by internal anal sphincter dysfunction, who failed treatment with bulking or constipating agents and pelvic floor physiotherapy. | 1 PTP injection into intersphincteric space and internal anal sphincter with guidance by endoanal ultrasound using 25 gauge hypodermic needles inserted to provide guidance to the position of intersphincteric space and the depth of insertion.; 2 PTP injection into intersphincteric space and internal anal sphincter without guidance by endoanal ultrasound | Self-reported fecal Wexner continence score (0 - perfect continence; 20 - complete incontinence), visual analog scale (10 being best) for global quality of life, fecal incontinence quality of life scales. | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of injectable silicone biomaterial, PTP to augment the internal anal sphincter. | Exclusion criteria: pregnancy, active perianal sepsis, unresected anorectal cancer, and immunosuppression.
Duration of followup: 3 months | Loss of followup: 14.6% at 3 months
O'Brien, 2004 ^804^ | 14 patients with severe fecal incontinence (the Cleveland Clinic Scoring System >15), mentally able to consent | 1 Placement of the artificial bowel sphincter activated at 6 weeks after surgery.; 2 Usual supportive care: physiotherapy, pelvic floor exercise, dietary advice. | Self-reported fecal Incontinence score using the Cleveland Clinic Scoring System (0 - perfect continence to 20 - complete incontinence). | Intention to treat not stated. Open label. Computer generated random numbers. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of an artificial bowel sphincter (Acticon Neosphincter) on fecal continence in severely incontinent adults. | Exclusion criteria: history of previous sphincter repair, chronic inflammation in perianal region, use of immunosuppressive drugs, inflammatory bowel disease, high anesthetic risk. | | American Medical Systems quality of life questionnaire specialized on fecal incontinence
Duration of followup: 6 months | Loss of followup: none
Muscle Transfer Procedures on FI
Effects of the surgical interventions (diversion) on fecal incontinence in adults with cancer
Seow-Choen, 1995 ^805^ | 40 patients with low rectal cancer and median distance from the lower edge of the tumor to the anal verge of 5cm. | 1 Ultra-low anterior resection with total mesorectal excision and 8cm J colonic pouch-anal anastomosis (median distance of anastomosis from the anal verge 3cm).; 2 Ultra-low anterior resection with total mesorectal excision and straight coloanal anastomosis (median distance of anastomosis from the anal verge 3.25cm). | Self-reported bowel urgency, fecal incontinence, pad use for fecal incontinence. | No Intention to treat. Open label. Randomization scheme not reported. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of ultra-low anterior resection with a J colonic pouch and straight coloanal anastomosis in patients with rectal cancer. | Exclusion criteria not reported.
Duration of followup after closure of ileostomy: 12 months | Loss of followup: 5%
Ho, 2001 ^806^ | 40 patients with adenocarcinoma of the mid and lower rectum. | 1 Standardized ultra-low anterior resection with straight coloanal anastomosis, the descending colon was anastomosed to the anorectal stump.; 2 Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Self-reported fecal incontinence using validated Wexner scale from 0 - continence to 24 - complete incontinence. Anal manometry outcomes. | No Intention to treat. Single blind. Randomization with random number table. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of colonic J-pouch and straight coloanal anastomosis after ultra-low anterior resection of rectal cancer. | Exclusion criteria: extensive local disease, which would preclude ultra-low anterior resection.
Duration of followup: 2 years | Loss of followup: 17%
Soliani,1992 ^807^ | 57 patients with left terminal colostomies at least 6 months after neoplastic or inflammatory diseases, trained for self-irrigation. | 1 Conseal Colostomy Plug fit with a two-piece Conseal system.; 2 Conseal Colostomy Plug fit with a one-piece Conseal system | Self-reported fecal incontinence as modification in continence time | No Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of Conseal Colostomy Plug, a new device for the regulation of continence in patients with colostomies. | Exclusion criteria: stomal pathology, short transit intestinal syndrome, not self independent, unreliable for correct colostomy handling.
Duration 2 weeks | Loss of followup: none
Hallbook, 1996 ^808^ | 100 patients with rectal adenocarcinoma, lower margin not more than 12cm from the anal verge with possible curative sphincter-saving resection. | 1 Low anterior resection with total mesorectal excision with straight anastomosis 6 to 8cm in length.; 2 Low anterior resection with total mesorectal excision colonic J pouch anastomosis 6 to 8cm in length. | Anastomotic leakage: abscess on CT scan or ultrasound; discharge of pus either per anum or through a fistula; and necessity of laparotomy or a transanal drainage procedure. Self-reported bowel function using questionnaire: Frequency of bowel movements per night. | No intention to treat. Single blind. Computer generated permuted block (4) randomization stratified for center and gender. Allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of a low anterior resection with either straight or colonic J pouch anastomosis in patients with rectal cancer. | Exclusion criteria: not reported. | | Degree of urgency: Ability to defer defecation for 30 minutes: always, often, sometimes, never.
Duration of followup after closure of ileostomy: 1 year | Loss of followup: 3% | | Composite score of grade and frequency of fecal incontinence (Miller scale). Ability to evacuate the bowel in <15 minutes: always, often, sometimes, never. Sensation of incomplete evacuation: never, sometimes, often, always. Impact on overall well-being: not at all, a little, quite a bit, very much.
Ho, 2002 ^809^ | 88 patients with mid- and low rectal adenocarcinoma. | 1 Standardized total mesorectal excision with at least 2cm of distal tumor clearance. J-pouch was constructed from descending colon 6cm in length using an Autosuture ILA 75 linear cutting stapler.; 2 Standardized total mesorectal excision with at least 2cm of distal tumor clearance. Coloplasty pouch was anastomosed to stapled anorectal stump. | Self-reported fecal continence score with validated Fecal Incontinence Quality of Life Scale, anorectal manometry, and endoanal ultrasound. | Intention to treat. Randomization with a computer-generated code. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of J-pouch and coloplasty pouch for low rectal cancer. | Exclusion criteria: extensive local disease, which would preclude ultralow anterior resection.
Duration of followup: 1 year. | Lost of followup: 23%, 7 deaths from chest infection and residual cancer
Machado, 2005 ^810^ | 71 patients with rectal cancer. | 1 Low anterior resection and total mesorectal excision with a colonic J-pouch anastomosis.; 2 Low anterior resection and total mesorectal excision with a colonic J-pouch or a side-to-end anastomosis. | Self-reported fecal incontinence using with scores from 0 to 18 (total incontinence). Bowel rank scores: number of bowel movements, incontinence scores, ability to defer defecation for 30 minutes and empty bowel for 15 minutes. | Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of colonic J-pouch or a side-to-end anastomosis after low anterior resection for rectal cancer. | Exclusion criteria: not reported. | | Anorectal manometry outcomes
Duration of followup: 2 years | Loss of followup: none.
Laurent, 2005 ^811^ | 37 patients with rectal adenocarcinoma requiring total mesorectal excision. | 1 Total mesorectal excision and hand sewn colonic J-pouch-anal anastomosis (6cm); 2 Total mesorectal excision and stapled colonic J-pouch-anal anastomosis (6cm) using PI-30 stapling instrument | Self-reported continence to gas, liquids, and solid stools Cleveland Clinic Fecal Incontinence Score Scale | No Intention to treat. Open label. Randomization in the operating room using computerized random number tables. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of staples or hand sewn colonic J-pouch-anal anastomosis for rectal cancer. | Exclusion criteria: distant metastases.
Duration of followup: 2 years | Loss of followup: 2.7%
Lazorthes, 1997 ^812^ | 59 consecutive patients with rectal cancers 4 to 8cm from the anal verge. | 1 Complete rectal excision with coloanal anastomosis 6cm J-pouch group; 2 Complete rectal excision with coloanal anastomosis 10cm J-pouch group | Self-reported bowel urgency and fecal continence | No Intention to treat. Open label. Randomization and allocation concealment not adequate. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of small and large colonic J-pouch following coloanal anastomosis on fecal incontinence in patients with rectal carcinoma. | Exclusion criteria: inadequate bowel length, thickened mesentery.
Duration of followup: 12, and 24 months after colostomy closure. | Loss of followup: 34%
McKee, 1992 ^813^ | 18 patients with full thickness prolapse of the rectum. | 1 Abdominal rectopexy without sigmoidectomy; 2 Abdominal rectopexy with sigmoidectomy of redundant sigmoid colon and end-to-end anastomosis of colon and rectum made in pelvic brim | Fecal incontinence using saline solution infusion test | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of abdominal rectopexy with and without sigmoidectomy in rectal prolapse. | Exclusion criteria: not reported.
Duration of followup: 20 months | Loss of followup: not reported
Furst, 2003 ^814^ | 40 patients with distal rectal cancer (<12cm from the anal verge) after low rectal resection and coloanal anastomosis. | 1 5cm colonic J-pouch constructed with a linear stapler; 2 8cm coloplasty pouch sutures horizontally with minimal extension effect. | Self-reported stool frequency. Anorectal manometry outcomes. | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of Colonic J-pouch and coloplasty in patients with resected distal rectal cancer. | Exclusion criteria: preoperative incontinence, inflammatory bowel diseases, adenocarcinoma of proximal rectum (>12cm above the anocutaneous line).
Duration of followup after closure of ileostomy: 6 months | Loss of followup: 25%
Hasegawa, 2000 ^815^ | 27 patients with fecal incontinence requiring sphincter repair due to localized sphincter damage. | 1 Fecal diversion with defunctioning stoma (closed at 4 months after surgery) for sphincter repair with standard overlapping technique; 2 Sphincter repair with standard overlapping technique with no stoma | Self-reported fecal Incontinence score using the Cleveland Clinic Scoring System (0 - perfect continence to 20 - complete incontinence). | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of fecal diversion after sphincter repair on fecal incontinence. | Exclusion criteria: not reported. | | Incontinence episodes as never; rarely if<1/month; sometime if <1/week; usually if >1/week; always if>1/day.
Duration of followup: 13 months | Loss of followup: none | | Anal manometry outcomes.
Sailer, 2002 ^816^ | 64 patients undergo low anterior rectal resection for primary cancer of the lower and middle third of the rectum. | 1 Total mesorectal excision and straight anastomosis with descending colon anastomosed in end-to-end fashion to the anal canal.; 2 Total mesorectal excision and coloanal J pouch anastomosis by folding the descending colon to the form of a ‘J’, 5 ± 6cm in length. | Self-reported fecal incontinence using Gastrointestinal Quality of Life Index (0–4 scale for 36 items with total 144 scores for nest outcome) European Organization for Research and Treatment of Cancer (EORTC) QLQ-C30) (0–100 scores for the best outcome) and disease-specific (EORTC QLQ-CR38) scales: 0–36 (perfect continence) | Intention-to treat. Open label. Randomization with computer-generated random clusters. Allocation concealment adequate. Sample size justified.
RCT to examine the effects of straight and pouch coloanal reconstruction. | Exclusion criteria: manifest or latent fecal incontinence.
Duration of followup: 3 months, 1 year | Loss of followup: 39%, 11 patients died.
Ho, 2002 ^817^ | 12 patients with mean age 61.5 years with adenocarcinoma of the mid and lower rectum. | 1 Standardized ultra-low anterior resection with straight coloanal anastomosis, the descending colon was anastomosed to the anorectal stump.; 2 Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Self-reported fecal incontinence using bowel questionnaire Anal manometry outcomes. | No Intention to treat. Single blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of colonic J-pouch and straight coloanal anastomosis after ultra-low anterior resection of rectal cancer. | Exclusion criteria: not reported. | | Scintigraphy with technetium TC 99m tin-colloid liquid test meal/I-131 microcapsule
Duration of followup: 1 year | Loss of followup: none
Furst, 2002 ^818^ | 74 consecutive patients (55 males) with rectal cancer in the lower and middle third of the rectum (<12cm above anocutaneuous line), local curative resection with preservation of sphincter, normal baseline continence. | 1 The standardized total mesorectal excision with preaortal lymph node dissection, autonomic nerve preservation, and short (5cm) colonic J-pouch anastomosis.; 2 The standardized total mesorectal excision with preaortal lymph node dissection, autonomic nerve preservation, and straight coloanal anastomosis. | Self report fecal incontinence using standardized questionnaire (European Organization for Research and Treatment of Cancer, EORTC-QLQ-C30). | No Intention to treat. Single blind. Randomization by independent person. Allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of short colonic J-pouch and straight coloanal anastomosis for low rectal cancer. | Exclusion criteria: inflammatory bowel disease, adenocarcinoma of proximal rectum (>12cm above anocutaneuous line). | | Anorectal manometry outcomes
Duration of followup: 6 months. | Loss of followup:16%, 6 deaths
Jiang 2005 ^819^ | 56 consecutive patients with middle-to-low rectal cancer eligible for local curative resection with possible sphincter preservation, and normal continence preoperatively, | 1 Side-to-end anastomosis after low anterior resection.; 2 Colonic J-pouch reconstruction after low anterior resection | Self-reported fecal incontinence. | No intention to treat. Randomization using random number table. Allocation concealment not reported. Baseline data confirmed the adequacy of randomization. Sample size not justified.
RCT to examine the effects of side-to-end or colonic J-pouch group on fecal incontinence in patients with rectal cancer. | Exclusion criteria: emergency admission. | | Anal manometry outcomes.
Duration of follow up: 2 years | Loss of follow up: 14.3% | | Continence was recorded as Grade 1 (perfect continence), Grade 2 (incontinence of flatus), Grade 3 (occasional minor soiling), Grade 4 (frequent major soiling), and Grade 5 (total incontinence).
Surgical interventions in patients with chronic ulcerative colitis
Reilly, 1997 ^820^ | 41 patients with chronic ulcerative colitis. | 1 Abdominal colectomy excising anal transition zone and hand sewing the pouch to the anal canal (Ileal Pouch-Anal Anastomosis).; 2 Abdominal colectomy preserving anal transition zone and double stapling the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Quality of life scores: 1 -severely restricted performance to 5 - improved performance. | Intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of staples or hand sewn techniques for excision of anal mucosa during ileas pouch-anal anastomosis. | Exclusion criteria: not reported. | | Anorectal manometry, scintigraphic outcomes and pudendal nerve terminal motor latency
Duration of followup: 6 months after closure of the temporary stoma. | Loss of followup: 22%
Johnston, 1996 ^821^ | 60 patients with ulcerative colitis. | 1–2. Duplicated (J) pelvic ileal reservoirs in restorative proctocolectomy constructed with either 30 or 40cm of ileum 3–4. Quadruplicated (W) reservoir pelvic ileal reservoirs in restorative proctocolectomy, constructed with either 30 or 40cm of ileum | Self-reported faecal leakage, anal soreness, the ability to defer defecation. | No Intention to treat. Single blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of duplicated and quadruplicated pelvic ileal reservoirs in restorative proctocolectomy for ulcerative colitis. | Exclusion criteria: not reported. | | Anorectal manometry outcomes.
Duration of followup after operation or closure of the defunctioning ileostomy: 1 year | Loss of followup: 5%
Selvaggi, 2000 ^822^ | 24 patients with ileal pouch-anal anastomosis for ulcerative colitis. | 1 Ileal pouch-anal anastomosis including total colectomy, total rectal excision, and two-limb J reservoir.; 2 Ileal pouch-anal anastomosis including total colectomy, total rectal excision, and four-limb W reservoir | Self-reported bowel function and fecal incontinence scores with Wexner scale from 0-continence to 24 - complete incontinence. | Intention to treat not stated. Single blind. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of J-pouch and W-pouch configurations for ulcerative colitis. | Exclusion criteria: not reported. | | Anorectal manometry outcomes.
Duration of followup after ileostomy closure: 1 year | Loss of followup: none
Oresland,1988 ^823^ | 40 patients with ulcerative proctocolitis 4 weeks after ileo-pouch anal anastomosis with J pouch extended to pelvis and sutured to pectinate line. | 1 Anal balloon dilatation with step-wise increasing pressure (5–80cm H20), distention ~ 60 seconds for 50–60 minutes.; 2 Sphincter training with visual feedback for 50–60 minutes/day. | Resting anal pressure, self-reported number of bowel evacuations. | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size not justified.
RCT to examine the effects of balloon dilatation of the pouch and sphincter biofeedback training in patients with an ileo-pouch anal anastomosis. | Exclusion criteria: not reported.
Duration: 8 weeks Duration of followup after closure of ileostomy: 1 year | Loss of followup: 5%.
Hahnloser, 2007 ^824^ | 1,885 patients with preoperative diagnosis of chronic ulcerative colitis operated with Ileal pouch-anal anastomosis - 1,824 J pouch, 44 S pouch, and 17 W pouch. A diverting ileostomy was performed in 98.4% of patients (30% one-stage procedure). | 1 Stage: abdominal colectomy, construction of ileal reservoir -J, S, or W pouch. Completion by excision of anal transition zone and hand sewing the pouch to the dentate line area, or by preserving anal transition zone and double -stapling the pouch to the dentate line.; 2 Stage: closure of the diverting stoma accomplished 2–3 months later. | Self-reported fecal incontinence during the day and night as never, occasional (1–2 episodes/ week), or frequent (>2 episodes per week). | Time-to-event and cumulative probability of remaining free from specific outcomes was estimated using the method of Kaplan and Meier, and survival curves were compared with the log rank test. No adjustment reported.
Retrospective analysis to analyze the effects of Ileal pouch-anal anastomosis for ulcerative colitis on fecal incontinence. | Loss of followup: response rates to the questionnaires by 1, 5, 10, 15, and 20 years were 80, 72, 73, 64, and 54%.
Duration of followup: 11 years.
Diversion in patients with rectal prolapse
McKee, 1992 ^813^ | 18 patients with full thickness prolapse of the rectum. | 1 Abdominal rectopexy without sigmoidectomy.; 2 Abdominal rectopexy with sigmoidectomy of redundant sigmoid colon and end-to-end anastomosis of colon and rectum made in pelvic brim | Fecal incontinence using saline solution infusion test | No intention to treat. Open label. Randomization and allocation concealment not reported. Baseline data not reported. Sample size not justified.
RCT to examine the effects of abdominal rectopexy with and without sigmoidectomy in rectal prolapse. | Exclusion criteria: not reported.
Duration of followup: 20 months | Loss of followup: not reported
Diversion in patients with sphincter damage
Hasegawa, 2000 ^815^ | 27 patients with fecal incontinence requiring sphincter repair due to localized sphincter damage. | 1 Fecal diversion with defunctioning stoma (closed at 4 months after surgery) for sphincter repair with standard overlapping technique.; 2 Sphincter repair with standard overlapping technique with no stoma | Self-reported fecal Incontinence score using the Cleveland Clinic Scoring System (0 - perfect continence to 20 - complete incontinence). | Intention to treat not stated. Open label. Randomization and allocation concealment not reported. Baseline data confirmed adequacy of randomization. Sample size justified.
RCT to examine the effects of fecal diversion after sphincter repair on fecal incontinence. | Exclusion criteria: not reported. | | Incontinence episodes as never; rarely if<1/month; sometime if <1/week; usually if >1/week; always if>1/day.
Duration of followup: 13 months | Loss of followup: none | | Anal manometry outcomes.

Table F152 Comparative effectiveness of conservative management of fecal incontinence in residents of nursing homes (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference, (95%CI) | % Difference from Control (95%CI)
Sample
Schnelle, 2002 ^459^ | Integrated incontinence care and exercise every 2 hours 5 days a week including fluid prompting, prompted toileting, and regular wet checks, arm raise and arm curl exercises | Usual care | Fecal incontinence frequency, % of wet checks | 3.0 ± 8.0 | 7.0 ±10.0 | -0.44 (-0.73;-0.15) | -6.3 (-0.4;-2.2)
N = 190
84% female
Schnelle, 1989 ^457^ | Prompted voiding treatment: check for incontinence, asking for needed toileting assistance, prompted voiding, and socially reinforced for appropriate toileting | Usual care | Percent wet checks/total checks | 17.8 ± 13.0 | 34.5 ± 16.8 | -1.1 (-1.5; -0.7) | -3.2 (-4.3; -2.1)
N = 126 | | | Percent appropriate toileting | 59.4 ± 26.7 | 16.8 ± 22.0 | 1.7 (1.3; 2.2) | 10.4 (7.9; 12.8)
75% female
Ouslander, 2005 ^458^ | Functional Incidental Training: prompted voiding combined with individualized, functionally oriented endurance and strength-training exercises offered 4 times per day, 5 days per week | Usual care | Wet checks/total checks | 25.0 ± 50.0 | 50.0 ± 28.0 | -0.6 (-1.0; -0.2) | -1.2 (-2.0; -0.5)
N = 107 | | | Wet stool checks/total checks | 0.0 ± 44.7 | 1.0 ± 22.0 | 0.0 (-0.4; 0.4) | -2.9 (40.8; 35.0)
10% female | | | Change after treatments in wet checks/ total checks | | | 17.0 (-83.9; 49.9)
| | | Change after treatments in wet stool checks/total checks | | | 0.0 (-46.0; 446.0)

Bold - significant difference in outcomes at 95% confidence level

Table F153 Comparative effectiveness of pharmacological intervention on progression of fecal incontinence in residents of long-term care unit

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STE After Control Treatment | Mean Difference from Control (95%CI)
Sample
Chassagne, 2000 ^720^ | Single osmotic laxative -30g lactulose | Osmotic agent 30g lactulose with a rectal stimulant (glycerine suppository) and weekly tap-water enemas | Episodes of fecal incontinence/ patient/day: loss of feces | 0.9 ± 0.4 | 0.8 ± 0.4 | 0.0 (-0.3; 0.4)
N = 178 | | | Episodes of fecal incontinence per patient/day: loss of feces | 0.4 ± 0.4 | 0.4 ± 0.5 | 0.0 (-0.4; 0.4)
82% female | | | Number of cloth changes/day due to fecal incontinence | 2.9 ± 0.6 | 2.8 ± 0.7 | 0.2 (-0.2; 0.5)

Table F154 Comparative effectiveness of individualized evidence-based conservative management on self-reported severity of fecal incontinence in patients after stroke

Author | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment
Sample
Harari, 2004 ^721^ | One or more episodes of FI per week | 3 | 3 | 4.10 | 4.10
N = 146 (Active = 73; Control = 73) | Straining on >1 in 4 bowel movements | 13 | 6 | 17.80 | 8.20
40% female

Table F155 Comparative effectiveness of individualized evidence-based conservative management on quality of life

Author | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference | Standard Error | P Value
Sample
Harari, 2004 ^721^ | Visual analog scale (0 = “no problem at all” to 100 = “terrible problem”) | 33.60 ± 30.9 | 32.00 ± 27.60 | 0.05 | 0.17 | 0.88
N=146 (Active = 73; Control = 73) | Visual analogue scale (0 = “no control” to 100 = “perfect control”) | 77.90 ± 24.70 | 73.90 ± 28.30 | 0.15 | 0.17 | 0.15
40% female

Table F156 Relative risk of fecal incontinence outcomes after individualized evidence-based conservative management

Author | Outcome | Relative Risk (95% CI
Harari, 2004 ^721^ | One or more episodes of FI per week | 1.13 (0.1; 8.9)
| Straining on >1 in 4 bowel movements | 1.51 (0.5; 4.9)

Table F157 Comparative effectiveness of dietary interventions on progression of fecal incontinence in adults (event rate)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI)
Sample
Bliss, 2001 ^722^ | Usual diet supplemented with 25g of Metamucil, 7.1g of psyllium/day | Usual diet supplemented with 0.25g of pectin/d as a placebo | % of incontinent stools | 2 | 7 | 17.0 | 50.0 | 0.3 (0.1; 1.2)
N = 42
80% female

Table F158 Comparative effectiveness of dietary interventions on progression of fecal incontinence in adults (severity measures)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Difference from Control (95%CI)
Sample
Bliss, 2001 ^722^ | Usual diet supplemented with 25g of Metamucil, 7.1g of psyllium/day | Usual diet supplemented with 0.25g of pectin/d as a placebo | Stool weight, g/day | 198.2 ± 6.9 | 139.0 ± 5.4 | 9.59 (6.77; 12.41) | 6.9 (4.9; 8.9)
N = 42 | | | Total stool solids, g/day | 34.1 ± 11.5 | 31.6 ± 11.5 | 0.22 (-0.55; 0.99) | 0.7 ( -1.8; 3.1)
80% female | | | % water content | 78.8 ± 4.7 | 77.0 ± 1.9 | 0.50 (-0.28; 1.28) | 0.7 (-0.4; 1.7)
| | | % water insoluble solids | 25.3 ± 7.9 | 22.9 ± 7.9 | 0.30 (-0.47; 1.08) | 1.3 (-2.1; 4.7)
| | | WHC/g water insoluble solids | 3.0 ± 0.4 | 2.3 ± 0.4 | 1.75 (0.84; 2.66) | 76.1 (36.3; 115.8)
| | | Total WHC | 46.6 ± 9.0 | 37.6 ± 9.0 | 1.00 (0.18; 1.82) | 2.7 (0.5; 4.8)
| Usual diet supplemented with 25g of gum arabic/day | | Stool weight, g/day | 159.0 ± 5.0 | 139.0 ± 5.4 | 3.83 (2.50; 5.16) | 2.8 (1.8; 3.7)
| | | Total stool solids, g/day | 35.6 ± 11.5 | 31.6 ± 11.5 | 0.35 (-0.43; 1.12) | 1.1 (-1.4; 3.6)
| | | % water content | 75.8 ± 4.7 | 77.0 ± 1.1 | -0.35 (-1.13; 0.42) | -0.5 (-1.5; 0.6)
| | | % water insoluble solids | 25.1 ± 7.9 | 22.9 ± 7.9 | 0.28 (-0.49; 1.05) | 1.2 (-2.2; 4.6)
| | | WHC/g water insoluble solids | 2.6 ± 0.4 | 2.3 ± 0.4 | 0.75 (-0.05; 1.55) | 32.6 (-2.1;67.3)
| | | Total WHC | 43.4 ± 9.0 | 37.6 ± 9.0 | 0.64 (-0.15; 1.43) | 1.7 (-0.4; 3.8)

WHC = Water holding capacity;

Bold- significant difference in outcomes at 95% confidence level

Table F159 Comparative effectiveness of conservative management programs on postnatal fecal incontinence in females

Author | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment
Sample
Glazener, 2001 ^483^ | 371 | 376 | Any fecal incontinence (to motions) | 12 | 25 | 4.40 | 10.50
N=747 | | | Severe fecal incontinence (sometimes, often, or always) | 5 | 12 | 1.80 | 5.10
100% female
Glazener, 2005 ^484^ | 371 | 376 | Fecal incontinence six years after index delivery | 32 | 32 | 12 | 13
N=747 | | | Severe fecal incontinence six years after index delivery | 15 | 8 | 6 | 3
100% female

Table F160 Relative risk of fecal incontinence outcomes, number needed to treat to prevent one event, and number of avoided (excessive) events per 1,000 treated after conservative management programs on postnatal fecal incontinence in females

Author | Outcome | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Glazener, 2001 ^483^ | Any fecal incontinence (to motions) | 0.49 (0.25; 0.95) | 16 (13; 206) | 61 (5;79)A
| Severe fecal incontinence (sometimes, often, or always) | 0.42 (0.15; 1.19)
Glazener, 2005 ^484^ | Fecal incontinence six years after index delivery | 1.0 (0.6; 1.6)
| Severe fecal incontinence six years after index delivery | 1.9 (0.8; 4.4)

Bold- significant difference in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F161 Comparative effectiveness self administered perineal massage on prevention of fecal incontinence in females

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Labrecque, 2000 ^482^ | Self administered perineal massage | Usual obstetric care | Fecal continence in women with no previous vaginal birth | 502 | 499 | 96.8 | 96.9 | 1.0 (1.0; 1.0)
Sample: 1034 | | | Fecal incontinence >1/day in women with no previous vaginal birth | 2 | 4 | 0.4 | 0.7 | 0.5 (0.1; 2.7)
Active: 519 | | | Fecal continence in women with previous vaginal birth | 242 | 237 | 98.4 | 95.8 | 1.0 (1.0; 1.1)
Control: 515 | | | Fecal incontinence >1/day in women with previous vaginal birth | 4 | 10 | 1.6 | 4.2 | 0.4 (0.1; 1.3)
Women with previous vaginal birth: 493
Active: 246
Control: 247

Table F162 Comparative effectiveness of behavioral interventions on prevention of fecal incontinence in females (cases of continence reported)

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Fynes, 1999 ^723^ | Augmented biofeedback training of pelvic floor with audiovisual feedback and electric stimulation of slow and fast twitch fibers | Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor exercise | 15 | 7 | 75.0 | 36.8 | 2.0 (1.1; 3.9) | 3 (1;37) | 382 (27; 1055)E
N = 40
100% female

Bold- significant difference in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient = 1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F163 Comparative effectiveness of behavioral interventions on instrumental outcomes in females

Author | Active Treatment | Control Treatment | Outcomes | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95%CI) | % Difference from Control (95%CI)
Sample
Fynes, 1999 ^723^ | Augmented biofeedback training of pelvic floor with audiovisual feedback and electric stimulation of slow and fast twitch fibers for 12 weeks | Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor exercise for 12 weeks | Mean maximum resting pressure | 54.0 ± 8.0 | 32.0 ± 16.8 | 1.69 (0.95; 2.42) | 5.3 (3.0; 7.6)
N = 40 | | | Mean maximum squeeze pressure | 86.0 ± 12.0 | 51.0 ± 29.6 | 1.56 (0.84; 2.29) | 3.1 (1.7; 4.5)
100% female | | | Squeeze increment | 30.0 ± 12.0 | 24.0 ± 4.2 | 0.66 (0.01; 1.31) | 2.8 (0.1; 5.4)
| | | Vector symmetry index | 0.5 ± 0.2 | 0.5 ± 0.2 | 0.00 (-0.63; 0.63) | 0.0 (-125.6; 125.6)

Bold- significant difference in outcomes at 95% confidence level

Table F164 Comparative effectiveness of behavioral interventions to prevent progression of fecal incontinence in females (events rate)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Ilnyckyj, 2005 ^724^ | Education and explanation and instruction in pelvic floor muscle strengthening exercises with max possible squeeze duration for 5 repetitions spaced by a 20 second pause, 6 times/day. | Education and visual and verbal biofeedback therapy using a radial catheter with a latex balloon | Self-reported success in bowel control: complete continence in bowel control-cured | 5 | 6 | 45.5 | 50.0 | 0.9 (0.4; 2.1)
N = 23
100% female

Table F165 Comparative effectiveness of behavioral intervention on prevention of fecal incontinence in adults (cases of continence reported)

Author | Active Treatment | Control Treatment | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI)
Sample
Norton, 2003 ^729^ | Hospital-based computer-assisted sphincter pressure biofeedback | Standard care with 9 40–60- minute sessions to advise on diet, fluid intake, bowel training | 2 | 0 | 5.0 | 0.1 | 3.8 (0.2; 76.9)
N = 171 | Standard care with 9 40–60-minute sessions to advise on diet, fluids intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | | 0.1 | 0.1
92% female | Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | 4 | 0 | 10.0 | 0.1 | 8.0 (0.4; 143.0)

Table F166 Comparative effectiveness of behavioral interventions to prevent progression of fecal incontinence adults (events rate)

Author | Active Treatment | Control Treatment | Outcomes | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95%CI)
Sample | | | | s
Byrne, 2005 ^726^ | Initial face-to-face assessment and treatment with transanal manometry and ultrasound biofeedback, followed by three treatments conducted via telephone and a final face-to-face assessment. | Standard treatment with 5 face-to-face treatment sessions with manometry and ultrasound | % improvement in Pascatori scores for fecal incontinence | 14 | 53 | 26.0 | 29.0 | 0.9 (0.5; 1.5)
N = 239 | | | % improvement in St Mark scores for fecal incontinence | 21 | 79 | 39.0 | 43.0 | 0.9 (0.6; 1.3)
90% female | | | % improvement in resting pressure | 2 | 15 | 3.0 | 8.0 | 0.4 (0.1; 1.9)
| | | % improvement in maximum pressure | 7 | 28 | 12.0 | 15.0 | 0.8 (0.4; 1.8)
| | | Marked Improvement in fecal incontinence | 12 | 50 | 22.0 | 27.0 | 0.8 (0.5; 1.4)
| | | Improved fecal incontinence | 21 | 54 | 39.0 | 29.0 | 1.3 (0.9; 2.0)
| | | No change in fecal incontinence | 19 | 80 | 35.0 | 43.0 | 0.8 (0.5; 1.2)
| | | Worse fecal incontinence | 2 | 2 | 4.0 | 1.0 | 3.4 (0.5; 23.3)
Norton, 2003 ^729^ | Hospital biofeedback plus the use of a home electromyelogr am biofeedback device once daily for 20 minutes | Standard care with 9 40–60- minute sessions to advise on diet, fluids intake, bowel training | Self-reported improvement in fecal incontinence | 23 | 20 | 55.0 | 55.0 | 1.0 (0.7; 1.5)
N = 171 | Hospital-based computerassisted sphincter pressure biofeedback | Standard care with 9 40–60- minute sessions to advise on diet, fluid intake, bowel training | Self-reported improvement in fecal incontinence | 27 | 20 | 55.0 | 55.0 | 1.0 (0.7; 1.5)
92% female | Standard care with 9 40–60- minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 19 | 20 | 45.0 | 55.0 | 0.8 (0.5; 1.3)

Table F167 Clinical behavioral interventions that resulted in improvement in fecal incontinence in more than 40% of subjects

Author | Treatment | % Improved
Sample
Byrne, 2005 ^726^ | Standard treatment with 5 face-to-face treatment sessions with manometry and ultrasound | 43.0
N = 239
90% female
Norton, 2003 ^729^ | Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | 45.0
N = 171 | Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | 55.0
92% female | Hospital-based computer-assisted sphincter pressure biofeedback | 55.0
| 40–60-minute sessions to advise on diet, fluid intake, bowel training | 55.0
Ilnyckyj, 2005 ^724^ | Education and explanation and instruction in pelvic floor muscle strengthening exercises with maximum possible squeeze duration for 5 repetitions spaced by a 20 second pause, 6 times/day | 45.5
N = 23 | Education and visual and verbal biofeedback therapy using a radial catheter with a latex balloon | 50.0
100% female

Table F168 Comparative effectiveness of behavioral interventions to prevent progression of fecal incontinence in adults (severity score measures and instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcomes | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Difference from Control (95% CI)
Sample
Byrne, 2002 ^725^ | Pelvic floor exercises and biofeedback | Baseline data | St Mark scores of quantitative fecal incontinence (0–10): socializing, shopping, outdoor activities | 6.8 ± 3.8 | 9.0 ± 2.7 | -0.67 (-0.93; -0.41) | -7.4 (-10.3; -4.5)
N = 120 | | | Pescatori scores of quantitative fecal incontinence (0–10): socializing, shopping, outdoor activities | 4.0 ± 1.6 | 4.9 ± 2.2 | -0.47 (-0.72; -0.21) | -9.5 (-14.8; -4.3)
91% female | | | St Mark scores of quantitative fecal incontinence (0–10): personal and psychological | 5.7 ± 3.6 | 7.6 ± 2.6 | -0.61 (-0.86; -0.35) | -8.0 (-11.4; -4.6)
| | | Pescatori scores of quantitative fecal incontinence (0–10): personal and psychological | 4.0 ± 1.6 | 4.6 ± 0.9 | -0.46 (-0.72; -0.21) | -10.0 (-15.6; -4.5)
| | | St Mark scores of quantitative fecal incontinence (0–10): travel | 8.0 ± 3.3 | 9.2 ± 2.1 | -0.43 (-0.69; -0.18) | -4.7 (-7.5; -1.9)
| | | Pescatori scores of quantitative fecal incontinence (0–10): travel | 4.6 ± 1.5 | 6.0 ± 1.5 | -0.93 (-1.20; -0.67) | -15.6 (-20.0; -11.1)
| | | St Mark scores of quantitative fecal incontinence (0–10): exercise | 7.7 ± 3.4 | 9.3 ± 2.7 | -0.52 (-0.78; -0.26) | -5.6 (-8.4; -2.8)
| | | Pescatori scores of quantitative fecal incontinence (0–10): exercise | 4.3 ± 1.5 | 4.7 ± 1.0 | -0.31 (-0.57; -0.06) | -6.7 (-12.1; -1.3)
| | | St Mark scores of quantitative fecal incontinence (0–10): family and relationship | 8.0 ± 3.5 | 9.3 ± 2.2 | -0.44 (-0.70; -0.19) | -4.8 (-7.5; -2.0)
| | | Pescatori scores of quantitative fecal incontinence (0–10): family and relationship | 4.5 ± 1.2 | 4.7 ± 0.7 | -0.20 (-0.46; 0.05) | -4.3 (-9.7; 1.1)
| | | St Mark scores of quantitative fecal incontinence (0–10): job and work | 6.3 ± 2.8 | 7.3 ± 2.8 | -0.36 (-0.61; -0.10) | -4.9 (-8.4; -1.4)
| | | Pescatori scores of quantitative fecal incontinence (0–10): job and work | 4.3 ± 1.1 | 4.6 ± 0.9 | -0.30 (-0.55; -0.04) | -6.5 (-12.0; -1.0)
Solomon, 2003 ^727^ | Biofeedback with transanal ultrasound | Pelvic floor exercises with feedback from digital examination alone | Pescatori fecal incontinence scores (0–6) | 4.0 ± 0.7 | 4.0 ± 0.7 | 0.00 (-0.44; 0.44) | 0.0 (-10.9; 10.9)
N = 120 | | | St Mark fecal incontinence scores (0–13) | 7.0 ± 1.3 | 8.0 ± 1.3 | -0.75 (-1.20; -0.30) | -9.4 (-15.0; -3.7)
89% female | | | Self-rated fecal incontinence (0–10) | 3.6 ± 1.1 | 3.5 ± 1.5 | 0.08 (-0.36; 0.51) | 2.2 (-10.3; 14.6)
| | | Investigator rated fecal incontinence (0–10) | 3.7 ± 2.1 | 4.5 ± 1.9 | -0.41 (-0.85; 0.03) | -9.0 (-18.8; 0.7)
| | | Rest pressure, mm/Hg | 44.0 ± 8.7 | 48.0 ± 6.0 | -0.54 (-0.98; -0.09) | -1.1 (-2.0; -0.2)
| | | Squeeze pressure, mm/Hg | 95.0 ± 17.3 | 90.0 ± 20.0 | 0.27 (-0.17; 0.70) | 0.3 (-0.2; 0.8)
| | | Isotonic fatigue time sec | 27.0 ± 10.0 | 15.0 ± 10.7 | 1.16 (0.69; 1.63) | 7.7 (4.6; 10.9)
| | | Isometric fatigue contractions (n) | 9.0 ± 2.7 | 8.0 ± 1.3 | 0.48 (0.03; 0.92) | 6.0 (0.4; 11.5)
| Biofeedback with anal manometry | | Pescatori fecal incontinence scores (0–6) | 4.0 ± 0.7 | 4.0 ± 0.7 | 0.00 (-0.44; 0.44) | 0.0 (-11.0; 11.0)
| | | St Mark fecal incontinence scores (0–13) | 6.0 ± 2.7 | 8.0 ± 1.3 | -0.96 ( -1.42; -0.49) | -12.0 (-17.7; -6.2)
| | | Self rated fecal incontinence (0–10) | 4.0 ± 1.2 | 3.5 ± 1.5 | 0.37 (-0.07; 0.81) | 10.6 (-2.0; 23.3)
| | | Investigator rated fecal incontinence (0–10) | 3.7 ± 2.5 | 4.5 ± 1.9 | -0.36 (-0.80; 0.08) | -8.0 (-17.8; 1.8)
| | | Rest pressure, mm/Hg | 45.0 ± 6.7 | 48.0 ± 6.0 | -0.47 (-0.92; -0.03) | -1.0 (-1.9; -0.1)
| | | Squeeze pressure, mm/Hg | 78.0 ± 18.7 | 90.0 ± 20.0 | -0.62 (-1.07; -0.17) | -0.7 (-1.2; -0.2)
| | | Isotonic fatigue time sec | 21.0 ± 6.7 | 15.0 ± 10.7 | 0.67 (0.22; 1.12) | 4.5 (1.5; 7.5)
| | | Isometric fatigue contractions (n) | 8.0 ± 1.3 | 8.0 ± 1.3 | 0.00 (-0.4; 0.44) | 0.0 (-5.5; 5.5)
Pager, 2002 ^728^ | Pelvic floor exercises with feedback from digital examination alone every day or 2–3 times/week. | 45 minute sessions of sphincter exercises with biofeedback (instrumental or digital examination) | Pescatori fecal incontinence score (0 as continent - 6) | 3.6 ± 1.8 | 3.0 ± 1.4 | 0.34 (-0.26; 0.94) | 11.4 (-8.6; 31.4)
N = 83 | | | St Mark Hospital Fecal incontinence score (0 as continent - 13) | 5.1 ± 3.7 | 3.8 ± 2.2 | 0.40 (-0.20; 1.00) | 10.6 (-5.2; 26.3)
89% female | | | Self-reported fecal continence (0 as continent - 10) | 3.3 ± 2.6 | 2.9 ± 2.4 | 0.18 (-0.42; 0.77) | 6.2 (-14.7; 27.2)
Norton, 2003 ^729^ | Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | Standard care with 9 40–60- minute sessions to advise on diet, fluid intake, bowel training | Rating of bowel control (0–10 scale) | 6.0 ± 2.2 | 6.0 ± 2.2 | 0 (-0.44; 0.44) | 0 (-7.4; 7.4)
N = 171 | Hospital-based computer-assisted sphincter pressure biofeedback | | | 6.0 ± 3.7 | 6.0 ± 2.2 | 0 (-0.43; 0.43) | 0 (-7.1; 7.1)
92% female | Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 7.0 ± 1.9 | 6.0 ± 2.2 | 0.49 (0.05; 0.94) | 8.2 (0.8; 15.6)
| Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | Diary fecal accidents per week | 0.1 ± 2.2 | 1.0 ± 1.5 | -0.47 (-0.92; -0.02) | -47.1 (-91.9; -2.3)
| Hospital-based computer-assisted sphincter pressure biofeedback | | | 0.0 ± 2.2 | 1.0 ± 1.5 | -0.52 (-0.95; -0.08) | -51.6 (-94.9; -8.2)
| Standard care with 9 40–60-minute sessions to advise on diet, fluids intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 0.1 ± 1.5 | 1.0 ± 1.5 | -0.61 (-1.06; -0.16) | -60.8 (-105.7; -15.8)
| Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | Diary pads/week for fecal incontinence | 0.1 ± 0.7 | 1.0 ± 1.5 | -0.78 (-1.24; -0.32) | -78.4 (-124.3; -32.5)
| Hospital-based computer-assisted sphincter pressure biofeedback | | | 0.1 ± 1.5 | 1.0 ± 1.5 | -0.61 (-1.04; -0.17) | -60.8 (-104.4; -17.1)
| Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 0.1 ± 0.1 | 1.0 ± 1.5 | -0.89 (-1.35; -0.43) | -89.2 (-135.3; -43.1)
| Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | Fecal continence score | 14.0 ± 8.1 | 13.0 ± 4.8 | 0.15 (-0.30; 0.59) | 1.1 (-2.3; 4.5)
| Hospital-based computer-assisted sphincter pressure biofeedback | | | 13.0 ± 5.2 | 13.0 ± 4.8 | 0.00 (-0.43; 0.43) | 0.0 (-3.3; 3.3)
| Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 11.0 ± 4.4 | 13.0 ± 4.8 | -0.43 (-0.88; 0.01) | -3.3 (-6.8; 0.1)
| Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | Resting pressure: cm H2O | 54.0 ± 33.3 | 50.0 ± 13.3 | 0.15 (-0.29; 0.60) | 0.3 (-0.6; 1.2)
| Hospital-based computer-assisted sphincter pressure biofeedback | | | 66.0 ± 26.7 | 50.0 ± 13.3 | 0.73 (0.29; 1.17) | 1.5 (0.6; 2.3)
| Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 49.0 ± 31.9 | 50.0 ± 13.3 | -0.04 (-0.48; 0.40) | -0.1 (-1.0; 0.8)
| Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | Squeeze increment: cm H_2_O | 37.0 ± 29.6 | 71.0 ± 49.6 | -0.84 (-1.31; -0.38) | -1.2 (-1.8; -0.5)
| Hospital-based computer-assisted sphincter pressure biofeedback | | | 30.0 ± 31.9 | 71.0 ± 49.6 | -1.01 (-1.47; -0.56) | -1.4 (-2.1; -0.8)
| Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 60.0 ± 76.3 | 71.0 | -0.17 (-0.61; 0.27) | -0.2 (-0.9; 0.4)
| Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | 5-second squeeze increment | 35.0 ± 37.0 | 35.0 ± 51.9 | 0 (-0.44; 0.44) | 0 (-1.3; 1.3)
| Hospital-based computer-assisted sphincter pressure biofeedback | | | 30.0 ± 33.3 | 35.0 ± 51.9 | -0.12 (-0.55; 0.31) | -0.3 (-1.6; 0.9)
| Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | | 37.0 ± 32.6 | 35.0 ± 51.9 | 0.05 (-0.39; 0.49) | 0.1 (-1.1; 1.4)
Jorge, 1994 ^730^ | Pelvic floor exercise program with 10 second contractions for 5 minutes 5 times/day before surgery | Regular care before surgery | Mean resting pressure, mm/Hg | 48.0 ± 64.9 | 44.0 ± 50.5 | 0.07 (-0.70; 0.84) | 0.2 (-1.6; 1.9)
N = 28 | | | Highest resting pressure. mm/Hg | 69.0 ± 90.1 | 65.0 ± 64.9 | 0.05 (-0.72; 0.82) | 0.1 (-1.1; 1.3)
39% female | | | Mean squeezing pressure, mm/Hg | 86.0 ± 194.7 | 110.0 ± 180.3 | -0.13 (-0.90; 0.64) | -0.1 (-0.8; 0.6)
| | | Highest squeezing pressure, mm/Hg | 118.0 ± 54.0 | 145.0 ± 50.0 | -0.52 (-1.30; 0.26) | -0.4 (-0.9; 0.2)
| | | Incontinence scores | 2.0 ± 1.2 | 2.8 ± 1.6 | -0.57 (-1.35; 0.22) | -20.2 (-48.2; 7.8)
Miner, 1990 ^731^ | Pelvic floor exercise with active sensory retraining (3 20-minute sessions) to perceive small rectal volumes of air into the rectal balloon | Pelvic floor exercise retraining with no instruction on how to improve performance. | Fecal incontinence episodes/week | 0.9 ± 1.1 | 2.3 ± 2.1 | -0.86 (-1.68; -0.03) | -37.2 (-73.0; -1.4)
N = 25 | | | Urgency episodes/week | 2.2 ± 5.0 | 3.9 ± 4.5 | -0.35 (-1.15; 0.44) | -9.1 (-29.4; 11.2)
68% female | | | Sensory threshold (ml) | 6.6 ± 7.6 | 19.5 ± 24.6 | -0.72 (-1.53; 0.09) | -3.7 (-7.9; 0.5)
| | | Sensory delay (seconds) | 0 | 3.7 ± 1.3 | | 0

Bold- significant difference in outcomes at 95% confidence level

Table F169 Comparative effectiveness of behavioral interventions on objective instrumental outcomes, only significant differences shown

Author | Treatment | Control | Outcomes | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95%CI) | % Change
Norton, 2003 ^729^ | Hospital-based computer-assisted sphincter pressure biofeedback | Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training | Squeeze increment: cm H2O | 30.0 ± 31.9 | 71.0 ± 49.6 | -1.01 (-1.47; - 0.56) | -1.4
| Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | Standard care with 9 40–60 minute sessions to advise on diet, fluid intake, bowel training | Squeeze increment: cm H_2_O | 37.0 ± 29.6 | 71.0 ± 49.6 | -0.84 (-1.31; - 0.38) | -1.2
Solomon, 2003 ^727^ | Biofeedback with transanal ultrasound | Pelvic floor exercises with feedback from digital examination alone | Rest pressure, mm/Hg | 44.0 ± 8.7 | 48.0 ± 6.0 | -0.54 (-0.98; - 0.09) | -1.1
| Biofeedback with anal manometry | Pelvic floor exercises with feedback from digital examination alone | Rest pressure, mm/Hg | 45.0 ± 6.7 | 48.0 ± 6.0 | -0.47 (-0.92; - 0.03) | -1.0
| | | Squeeze pressure, mm/Hg | 78.0 ± 18.7 | 90.0 ± 20.0 | -0.62 (-1.07; - 0.17) | -0.7
Norton, 2003 ^729^ | Hospital-based computer-assisted sphincter pressure biofeedback | Standard care with 9 40–60 minute sessions to advise on diet, fluid intake, bowel training | Resting pressure: cm/H_2_O | 66.0 ± 26.7 | 50.0 ± 13.3 | 0.73 (0.29; 1.17) | 1.5
Fynes, 1999 ^723^ | Augmented biofeedback training of pelvic floor with audiovisual feedback and electric stimulation of slow and fast twitch fibers | Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor exercise for 12 weeks | Squeeze increment | 30.0 ± 12.0 | 24.0 ± 4.2 | 0.66 (0.01; 1.31) | 2.8
| Augmented biofeedback training of pelvic floor with audiovisual feedback and electric stimulation of slow and fast twitch fibers for 12 weeks | Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor exercise for 12 weeks | Mean maximum squeeze pressure | 86.0 ± 12.0 | 51.0 ± 29.6 | 1.56 (0.84; 2.29) | 3.1
Solomon, 2003 ^727^ | Biofeedback with anal manometry | Pelvic floor exercises with feedback from digital examination alone | Isotonic fatigue time seconds | 21.0 ± 6.7 | 15.0 ± 10.7 | 0.67 (0.22; 1.12) | 4.5
Fynes, 1999 ^723^ | Augmented biofeedback training of pelvic floor with audiovisual feedback and electric stimulation of slow and fast twitch fibers for 12 weeks | Sensory biofeedback training with a vaginal perineometer and standard Kegel pelvic floor exercise for 12 weeks | Mean maximum resting pressure | 54.0 ± 8.0 | 32.0 ± 16.8 | 1.69 (0.95; 2.42) | 5.3
Solomon, 2003 ^727^ | Biofeedback with transanal ultrasound | Pelvic floor exercises with feedback from digital examination alone | Isometric fatigue contractions (n) | 9.0 ± 2.7 | 8.0 ± 1.3 | 0.48 (0.03; 0.92) | 6.0
| | | Isotonic fatigue time seconds | 27.0 ± 10.0 | 15.0 ± 10.7 | 1.16 (0.69; 1.63) | 7.7
Norton, 2003 ^729^ | Standard care with 9 40–60 minute sessions to advise on diet, fluid intake, bowel training plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | Standard care with 9 40–60 minute sessions to advise on diet, fluid intake, bowel training | Rating of bowel control (0–10 scale) | 7.0 ± 1.9 | 6.0 ± 2.2 | 0.49 (0.05; 0.94) | 8.2

Bold- significant difference in outcomes at 95% confidence level

Table F170 Clinical behavioral interventions that resulted in more than 40% difference in outcome levels compared to standard care ^729^

Active Treatment | Outcome | Mean ± STD After Active Treatment | % Difference from Control (95% CI)
Standard care with 9 40–60 minute sessions to advise on diet, fluid intake, bowel training, plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | Diary record of pads per week for fecal incontinence | 0.1 ± 0.1 | -89.2 (-135.3; -43.1)
Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | 0.1 ± 0.7 | -78.4 (-124.3; -32.5)
Standard care with 9 40–60-minute sessions to advise on diet, fluid intake, bowel training, plus instruction on sphincter exercises with at least 50 maximal voluntary sustained sphincter contractions and 50 fast-twitch contractions per day | | 0.1 ± 1.5 | -60.8 (-105.7; -15.8)
Hospital-based computer-assisted sphincter pressure biofeedback | | 0.1 ± 1.5 | -60.8 (-104.4; -17.1)
Hospital-based computer-assisted sphincter pressure biofeedback | Diary record of fecal accidents per week | 0.0 ± 2.2 | -51.6 (-94.9; -8.2)
Hospital biofeedback plus the use of a home electromyelogram biofeedback device once daily for 20 minutes | | 0.1 ± 2.2 | -47.1 (-91.9; -2.3)

Bold- significant difference in outcomes at 95% confidence level

Table F171 Comparative effectiveness of electrical stimulation on fecal incontinence in adults (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment
Sample
Norton, 2006 ^732^ | Active anal stimulation at 35Hz and 40 minutes per day | Sham anal stimulation at 1Hz | Cured from fecal incontinence | 1 | 0 | 2.5 | 0.1
N = 90
100% female
Stamp, 2001 ^574^ | Massage and stretching of the perineum during the second stage of labor with a water soluble lubricant | Usual care | Fecal incontinence 3 months postpartum | 36 | 35 | 5.1 | 5.5
N = 1,340
100% female
Norton, 2006 ^732^ | Active anal stimulation at 35Hz and 40 minutes per day | Sham anal stimulation at 1Hz | Significant improvement in fecal incontinence | 5 | 7 | 10.0 | 16.0
N = 90 | | | Small improvement in fecal incontinence | 17 | 14 | 36.0 | 32.0
90% female
Leroi, 2005 ^733^ | Active sacral nerve continuous stimulation with pulse width of 210 microseconds, frequency 14 pulses/second, and amplitude adapted to the patient's perception of perineal and anal sphincter muscle contraction. | Sham sacral nerve stimulation with lead turned off | Improvement in fecal incontinence | 30 | 6 | 89.0 | 17.0
N = 34
91% female
Healy, 2006 ^735^ | Endo-anal electrical stimulation using a home-based unit | Endo-anal hospital-supervised electrical stimulation | Fecal incontinence much better | 17 | 20 | 60.00 | 68.00
N = 58 | Endo-anal electrical stimulation using a home-based unit | Endo-anal hospital-supervised electrical stimulation | Cured fecal incontinence | 1 | 0 | 5.00 | 0.01
100% female

Table F172 Relative effectiveness and attributable events of electrical stimulation on fecal incontinence in adults

Author | Active Treatment | Control Treatment | Outcome | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Norton, 2006 ^732^ | Active anal stimulation at 35Hz and 40 minutes per day | Sham anal stimulation at 1 Hz | Cured from fecal incontinence | 2.8 (0.1; 65.8)
N = 90
100% female
Stamp, 2001 ^574^ | Massage and stretching of the perineum during the second stage of labour with a water soluble lubricant | Usual care | Fecal incontinence 3 months postpartum | 0.9 (0.6; 1.4)
N = 1,340
100% female
Norton, 2006 ^732^ | Active anal stimulation at 35Hz and 40 minutes per day | Sham anal stimulation at 1Hz | Significant improvement in fecal incontinence | 0.7 (0.2; 1.9)
N = 90 | | | Small improvement in fecal incontinence | 1.1 (0.6; 2.0)
90% female
Leroi, 2005 ^733^ | Active sacral nerve continuous stimulation with pulse width of 210 microseconds, frequency 14 pulses/second, and amplitude adapted to the patient's perception of perineal and anal sphincter muscle contraction. | Sham sacral nerve stimulation with lead turned off | Improvement in fecal incontinence | 5.0 (2.4; 10.4) | 1 (1; 4) | 720 (237; 1,605)E
N = 34
91% female
Healy, 2006 ^735^ | Endo-anal electrical stimulation using a home-based unit | Endo-anal hospital-supervised electrical stimulation | Fecal incontinence much better | 0.85 (0.57; 1.26)
N = 58 | Endo-anal electrical stimulation using a home-based unit | Endo-anal hospital-supervised electrical stimulation | Cured fecal incontinence | 3.00 (0.13; 70.74)
100% female
Folloup: 3

Bold- significant difference in outcomes at 95% confidence level;

A - Number of avoided; E - number of excessive events per 1000 treated

Table F173 The effect of electrical stimulation on quality of life of fecal incontinence in adults

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Changes from Control (95% CI)
Sample
Leroi, 2005 ^733^ | Active sacral nerve continuous stimulation with pulse width of 210 microseconds, frequency 14 pulses/second, and amplitude adapted to the patient's perception of perineal and anal sphincter muscle contraction. | Sham sacral nerve stimulation with lead turned off | Bowel movements/week | 10.2 ± 10.5 | 12.7 ± 4.2 | -0.3 (-0.8; 0.2) | -2.5 ( -6.2; 1.3)
N = 34 | | | Fecal Incontinent episodes/week | 0.7 ± 2.9 | 1.7 ± 6.2 | -0.2 (-0.7; 0.3) | -12.2 (-40.2; 15.9)
91% female | | | Fecal urgency episodes/week | 1.0 ± 10.0 | 4.5 ± 3.7 | -0.5 (-0.9; 0.0) | -10.3 (-21.0; 0.4)
| | | Delay to postpone defecation | 1.8 ± 0.8 | 1.0 ± 1.3 | 0.7 (0.2; 1.2) | 72.8 (23.6; 121.9)
| | | Cleveland Clinic score | 8.0 ± 4.7 | 15.0 ± 0.0 | | 0.0 (0.0; 0.0)
Mahony, 2005 ^736^ | Intra-anal electromyographic biofeedback with electrical stimulation of the anal sphincter weekly for 12 weeks | Standard intraanal electromyographic biofeedback training of the pelvic floor | Median scores of fecal incontinence | 2.0 ± 6.4 | 2.0 ± 6.4 | 0.0 (-0.5; 0.5) | 0.0 (-26.7; 26.7)
N = 60
100% female
Chang, 2003 ^734^ | External electrical stimulation therapy using an anal plug with pulse generator in the anal canal once a day for 20 minutes over 10–12 sessions with pulse width of 360–960 μs, a frequency of 2–110Hz, and an amplitude of 30–35 V. | Biofeedback therapy using the EMG system. The visual feedback observing changes in pressure activity on a monitor screen during rise in rectal pressure synchronized with anal relaxation for 60–90 mutes in over 10–14 sessions. | Satisfaction with bowel habits | 48.3 ± 34.1 | 59.0 ± 28.8 | -0.3 (-1.2; 0.5) | -0.6 (-2.0; 0.9)
N = 22 | | | Incomplete evacuation score: 0–10 (0=absent, 10 = very severe) | 4.2 ± 3.0 | 4.5 ± 3.3 | -0.1 (-0.9; 0.7) | -2.1 (-20.8; 16.5)
50% female

Bold- significant difference in outcomes at 95% confidence level

Table F174 Effects of electrical stimulation on progression of fecal incontinence in adults (anal manometry outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Changes from Control (95% CI)
Sample
Norton, 2006 ^732^ | Active anal stimulation at 35 Hz and 40 minutes per day | Sham anal stimulation at 1 Hz | Anal manometry: resting pressure | 49.0 ± 18.0 | 38.5 ± 18.0 | 0.6 (0.2; 1.0) | 1.5 (0.4; 2.6)
N = 90 | | | Anal manometry: squeeze pressure increment | 50.0 ± 15.2 | 36.5 ± 5.1 | 1.2 (0.7; 1.6) | 3.2 (2.0; 4.4)
90% female | | | Cough pressure increment | 56.0 ± 22.9 | 40.5 ± 7.7 | 0.9 (0.5; 1.3) | 2.2 (1.1; 3.3)
Leroi, 2005 ^733^ | Active sacral nerve continuous stimulation with pulse width of 210 microseconds, frequency 14 pulses/sec, and amplitude adapted to the patient's perception of perineal and anal sphincter muscle contraction | Sham sacral nerve stimulation with lead turned off | Maximum resting pressure (cm/H2O) | 50.0 ± 70.0 | 50.0 ± 32.0 | 0.0 (-0.5; 0.5) | 0.0 (-1.0; 1.0)
N = 34 | | | Maximum squeeze pressure increment (cmH2O) | 53.0 ± 182.0 | 54.0 ± 37.3 | 0.0 (-0.5; 0.5) | 0.0 (-0.9; 0.9)
91% female | | | Squeeze pressure duration (seconds) | 18.0 ± 49.3 | 40.0 ± 0.0 | | 0.0 (0.0; 0.0)
Mahony, 2004 ^736^ | Intra-anal electromyographic biofeedback with electrical stimulation of the anal sphincter weekly for 12 weeks | Standard intra-anal electromyographic biofeedback training of the pelvic floor | Median resting pressure (mm/Hg) | 30.0 ± 28.8 | 31.0 ± 26.4 | 0.0 (-0.6; 0.5) | -0.1 (-1.8; 1.6)
N = 60 | | | Median squeeze pressure (mm/Hg) | 47.0 ± 35.2 | 59.0 ± 40.8 | -0.3 (-0.9; 0.2) | -0.5 (-1.4; 0.4)
100% female
Chang, 2003 ^734^ | External electrical stimulation therapy using an anal plug with pulse generator in the anal canal once a day for 20 min over 10–12 sessions with pulse width of 360–960 μs, a frequency of 2–110Hz, and an amplitude of 30–35V | Biofeedback therapy using the EMG system. The visual feedback observing changes in pressure activity on a monitor screen during rise in rectal pressure synchronized with anal relaxation for 60–90 minutes over 10–14 sessions. | Mean anal resting pressure | 58.2 ± 16.5 | 69.5 ± 46.4 | -0.3 (-1.2; 0.5) | -0.5 (-1.7; 0.7)
N = 22 | | | Maximal anal squeezing pressure | 176.4 ± 50.3 | 177.2 ± 42.7 | 0.0 (-0.9; 0.8) | 0.0 (-0.5; 0.5)
50% female | | | Anal residual pressure | 63.6 ± 45.9 | 38.0 ± 21.5 | 0.7 (-0.2; 1.6) | 1.8 (-0.5; 4.1)
| | | Rectal pressure | 38.0 ± 21.5 | 58.5 ± 24.8 | -0.9 (-1.8; 0.0) | -1.5 (-3.0; 0.0)
| | | Rectal sensory threshold volumes (ml): first perception | 10.0 ± 0.0 | 10.0 ± 0.0 | | 0.0 (0.0; 0.0)
| | | Rectal sensory threshold volumes (ml): desire to defecate | 70.0 ± 29.9 | 99.0 ± 31.7 | -0.9 (-1.8; -0.1) | -1.0 (-1.9; -0.1)
| | | Rectal sensory threshold volumes (ml): urge to defecate | 135. ± 47.9 | 160.0 ± 44.9 | -0.5 (-1.4; 0.3) | -0.3 (-0.9; 0.2)
| | | Rectal sensory threshold volumes (ml): maximal tolerated volume | 174.0 ± 58.5 | 205.0 ± 60.9 | -0.5 (-1.4; 0.3) | -0.3 (-0.7; 0.2)

Bold- significant difference in outcomes at 95% confidence level

Table F175 Comparative effectiveness of Botulinum toxin on fecal incontinence (events rate)

Author | Active | Control | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Ratio (%) After Active Treatment | Ratio (%) After Control Treatment | Relative Risk (95% CL)
Sample
Mentes, 2003 ^740^ | 20 to 30 U (~ 0.3 U/kg) of type A botulinum toxin (Botox) injection into the internal anal sphincter. The injection was repeated 2 months later if complete healing was not achieved. | Lateral internal anal sphincterotomy | Self-reported incidence of fecal incontinence | 5 | 0 | 8 | 0 | 9.0 (0.5; 159.8)
N = 111
68% female
Ron, 2001 ^739^ | Local injection of Botox-10 units to each side of the puborectalis | Local injection of Botox-20 units to the posterior aspect of this muscle. | Self-reported fecal continence | 15 | 11 | 100 | 100
N = 25
60% female

Table F176 Comparative effectiveness of pharmacological interventions on progression of fecal incontinence (severity measures and instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI)
Sample
Iswariah, 2005 ^741^ | Botox, 20 units injected on either side of the fissure into the internal anal sphincter. | Sphincterotomy by open or closed technique in the left lateral position using Park's anal retractor | Self-reported modified Wexner Fecal Continence scoring system | 0.2 ± 1.2 | 0.0 ± 0.0 | 0.2 (-0.4; 0.9)
N = 44
58% female
Brisinda, 1999 ^742^ | 20 U of Botulinum toxin injected into the internal anal sphincter on each side of the anterior midline | 0.2% nitroglycerin ointment applied twice daily | Resting anal pressure | 64.2 ± 14.9 | 71.9 ± 17.0 | -0.5 (-1.0; 0.1)
N = 50 | | | Maximal Voluntary pressure | 83.3 ± 25.2 | 86.5 ± 31.3 | -0.1 ( -0.7; 0.4)
50% female
Nessim, 1999 ^749^ | Medical bowel confinement: clear liquid diet with loperamide 4mg 3 times/day and codeine phosphate 30 mg 4 times/day for 3 days. | Regular diet beginning the day of surgery | Fecal incontinence scores (1–20) | 6.0 ± 9.3 | 5.0 ± 4.7 | 0.1 (-0.6; 0.8)
N = 54
85% female
Sun, 1997 ^745^ | Loperamide oxide 4mg twice daily | Placebo | Fecal urgency in Visual analog scale from 0 (absent) to 100 (extreme). | 40.0 ± 35.0 | 70.0 ± 25.0 | -1.0 (-1.9; -0.1)
N = 11 | | | | 26.0 ± 36.0 | 43.0 ± 37.0 | -0.5 (-1.3; 0.4)
73% female | | | Maximal anal pressure, cm H20 | 76.0 ± 40.0 | 69.0 ± 35.0 | 0.2 (-0.7; 1.0)
| | | minimum basal pressure, cm H20 | 58.0 ± 28.0 | 48.0 ± 28.0 | 0.4 (-0.5; 1.2)
| | | Squeeze increment, cm H20 | 107.0 ± 66.0 | 104.0 ± 61.0 | 0.0 (-0.8; 0.9)
| | | Total squeeze pressure, cm H20 | 163.0 ± 86.0 | 155.0 ± 85.0 | 0.1 (-0.7; 0.9)
Hallgren, 1994 ^744^ | Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days in hand sewn ileal pouch-anal anastomosis | Placebo with the same frequency in hand sewn ileal pouch-anal anastomosis | Maximal squeeze pressure | 240.0 ± 21.9 | 245.0 ± 24.9 | -0.2 (-0.9; 0.5)
N = 30 | Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days after abdominal proctocolectomy and stapling of the pouch to the top of the anal canal | Placebo with the same frequency after abdominal proctocolectomy and stapling of the pouch to the top of the anal canal | Maximal squeeze pressure | 210.0 ± 31.7 | 165.0 ± 56.2 | 1.0 (0.2; 1.7)
27% female
Ho, 2005 ^737^ | Chemical sphincterotomy with oral nifedipine 20mg twice a day for 6 weeks. | Lateral sphincterotomy | Fecal continence scores, Wexner | 0.4 ± 2.6 | 0.2 ± 0.7 | 0.1 (-0.3; 0.5)
N = 89 | | | Mean resting anal pressure, mm/Hg | 42.7 ± 43.5 | 43.4 ± 27.7 | 0.0 (-0.4; 0.4)
83% female | | | Mean squeeze pressure, mm/Hg | 162.1 ± 123.6 | 199.8 ± 178.7 | -0.2 (-0.7; 0.2)
Tankova, 2002 ^750^ | Rectal administration of hydrogel containing 0.2% isosorbide-5-mononitrate 2 times/day | Placebo gel. | Resting anal pressure | 27.9 ± 4.0 | 34.5 ± 6.5 | -1.2 (-2.2; -0.3)
N = 19
58% female
Carapeti, 2000 ^748^ | Alpha1-adrenergic agonist phenylephrine, topical 10 percent 0.5ml application 2 times/day | Placebo gel | Fecal Incontinence score (0-continence to 24 - complete incontinence) | 9.0 ± 3.0 | 20.0 ± 1.0 | -4.6 (-6.9; -2.3)
N = 12 | | | Fecal incontinence symptom score (0- no symptoms to 280) | 117.0 ± 36.0 | 208.0 ± 31.0 | -2.7 (-4.3; -1.0)
58% female | | | Max resting pressure mm H20 | 91.0 ± 7.0 | 78.0 ± 17.0 | 1.0 (-0.1; 2.1)
| | | Max resting pressure mm H20 | 86.0 ± 27.0 | 71.0 ± 9.0 | 0.7 (-0.5; 2.0)
Carapeti, 2000 ^747^ | Topical 10 % phenylephrine 0.5ml applied topically to the anus twice daily for 4 weeks | Identical placebo gel 0.5ml applied topically to the anus twice daily for 4 weeks | Self-reported fecal incontinence score Wexner scale: 24- worst incontinence; active-placebo | 12.5 ± 3.4 | 12.6 ± 4.2 | 0.0 (-0.7; 0.6)
N = 36 | | | maximum resting anal pressure, H20; active-placebo | 65.0 ± 21.0 | 54.0 ± 21.0 | 0.5 (-0.1; 1.2)
61% female | | | Self-reported fecal incontinence score Wexner scale: 24- worst incontinence; active-placebo | 13.0 ± 4.7 | 13.4 ± 4.7 | -0.1 (-0.7; 0.6)
| | | maximum resting anal pressure, H20; active-placebo | 55.0 ± 16.0 | 61.0 ± 18.0 | -0.4 (-1.0; 0.3)

Bold- significant difference in outcomes at 95% confidence level

Table F177 Comparative effectiveness of Loperamide vs. placebo on fecal incontinence (events rate)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CL)
Sample
Hallgren, 1994 ^744^ | Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days in hand sewn ileal pouch-anal anastomosis | Placebo with the same frequency in hand sewn ileal pouch-anal anastomosis | Fecal leak/soiling day time | 1 | 3 | 7 | 20 | 0.3 (0.0; 2.9)
N = 30 | | | Fecal leak/soiling night time | 1 | 5 | 7 | 34 | 0.2 (0.0; 1.5)
27% female | | | Use of pad for fecal incontinence daytime | 1 | 1 | 7 | 7 | 1.0 (0.1; 14.6)
| | | Use of pad for fecal incontinence night time | 1 | 2 | 7 | 14 | 0.5 (0.1; 4.9)
| Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days after abdominal proctocolectomy and stapling of the pouch to the top of the anal canal | Placebo with the same frequency after abdominal proctocolectomy and stapling of the pouch to the top of the anal canal | Fecal leak/soiling day time | 2 | 5 | 15 | 31 | 0.4 (0.1; 1.7)
| | | Fecal leak/soiling night time | 0 | 7 | 0 | 46 | 0.1 (0.0; 1.1)
| | | Use of pad for fecal incontinence daytime | 0 | 2 | 0 | 15 | 0.2 (0.0; 3.8)
| | | Use of pad for fecal incontinence night time | 0 | 5 | 0 | 31 | 0.1 (0.0; 1.5)

Table F178 Comparative effectiveness of pharmacological interventions on fecal incontinence (events rate)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CL) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Tankova, 2002 ^750^ | Rectal administration of hydrogel containing 0.2% isosorbide-5- mononitrate 2 times/day | Placebo gel | Anal fissure healing | 8 | 2 | 80.0 | 22.0 | 4 ( 1; 13) | 2 (225; 0) | 580 (4; 2,575)E
N = 19 | | | Self-reported fecal continence | 10 | 9 | 100.0 | 100.0
58% female
De Nardi, 2006 ^738^ | “Chemical sphincterotomy” with 0.2 percent glycerine trinitrate ointment applied three times daily at the anal margin for 8 weeks | “Chemical sphincterotomy” with 20 units Botulinum toxin A injection into the internal anal sphincter on each side of the anterior midline | Self-reported fecal continence | 15 | 15 | 100.0 | 100.0
N = 30
43% female
Kneebone, 2004 ^746^ | 3g of oral sucralfate suspension twice daily starting 1 day before RT and continuing every day for 8 weeks | Identical placebo twice daily | Fecal incontinence (Grade 1 or worse) | 51 | 55 | 33.0 | 33.0 | 1 ( 1; 1)
N = 338 | | | Fecal incontinence (any/3 months) | 16 | 20 | 10.3 | 12.1 | 1 (0; 2)
0% female | | | Incidence of any fecal incontinence | 17 | 27 | 11.0 | 16.0 | 1 (0; 1)
Carapeti, 2000 ^747^ | Topical 10% phenylephrine 0.5 ml applied topically to the anus twice daily for 4 weeks | Identical placebo gel 0.5 ml applied topically to the anus twice daily for 4 weeks | Improvement in fecal incontinence symptoms >75% | 6 | 2 | 33.3 | 11.1 | 3 (1; 13)
N = 36
61% female

Bold- significant differences in outcomes at 95% confidence level;

A - Number of avoided; E - number of excessive events per 1000 treated

Table F179 Medications that resulted in fecal continence in more than 50% of subjects

Author | Definition of Continence | Treatment | % Continent
Sample
Kneebone, 2004 ^746^ | Fecal continence with Grade <1 | 3g of oral sucralfate suspension twice daily starting 1 day before RT and continuing every day for 8 weeks | 67
N = 338 | Absence of any fecal incontinence at 2 years | 3g of oral sucralfate suspension twice daily starting 1 day before RT and continuing every day for 8 weeks | 89
0% female | Absence of any fecal incontinence at 3 months | 3g of oral sucralfate suspension twice daily starting 1 day before RT and continuing every day for 8 weeks | 89.7
Hallgren, 1994 ^744^ | No fecal leak/soiling in day time | Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days after abdominal proctocolectomy and stapling of the pouch to the top of the anal canal | 85
N = 30 | | Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days in hand sewn ileal pouch-anal anastomosis | 93
27% female | No fecal leak/soiling night time | Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days in hand sewn ileal pouch-anal anastomosis | 93
| | Loperamide hydrochloride (Imodium) 2mg 2 capsules 3 times/day for 7 days after abdominal proctocolectomy and stapling of the pouch to the top of the anal canal | 99.9
Mentes, 2003 ^740^ | Fecal continence | 20 to 30 units (~0.3 U/kg) of type A Botulinum toxin (Botox) injection into the internal anal sphincter. The injection was repeated 2 months later if complete healing was not achieved | 92
N = 111
68% female
De Nardi, 2006 ^738^ | Fecal continence | “Chemical sphincterotomy” with 0.2% glycerine trinitrate ointment applied three times daily at the anal margin for 8 weeks | 100
N = 30 | | “Chemical sphincterotomy” with 20 units Botulinum toxin A injection into the internal anal sphincter on each side of the anterior midline | 100
43% female

Table F180 Medications that changed self-reported scores of fecal incontinence by more than 20% compared to the control interventions

Author | Active Treatment | Control Treatment | Outcome | Mean ± After Active Treatment | Mean ± After Control Treatment | Mean Difference (95% CI) | % Change from Control
Sample
Carapeti, 2000 ^748^ | Alpha1-adrenergic agonist phenylephrine, topical 10% 0.5ml application 2 times/day | Placebo gel | Fecal incontinence score (0- continence to 24 - complete incontinence) | 9.0 ± 3.0 | 20.0 ± 1.0 | -4.6 (-6.9; -2.3) | -22.8
N = 12
58% female
Ho, 2005 ^737^ | Chemical sphincterotomy with oral nifedipine 20 mg twice a day for 6 weeks | Lateral sphincterotomy | Fecal continence scores, Wexner | 0.4 ± 2.6 | 0.2 ±0.7 | 0.1 (-0.3; 0.5) | 55.3
N = 89
83% female
Iswariah, 2005 ^741^ | Botox, 20 units injected on either side of the fissure into the internal anal sphincter | Sphincterotomy by open or closed technique in the left lateral position using Park's anal retractor | Self-reported modified Wexner fecal continence scoring system | 0.2 ± 1.2 | 0.0 ± 0.0 | 0.2 (-0.4; 0.9) | 2107.3
N = 44
58% female

Bold- significant difference in outcomes at 95% confidence level

Table F181 Comparative effectiveness of end-to-end technique vs. overlapping repair of obstetric anal sphincter lacerations (clinical events)

Author | Outcome | Number of Cases After-Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Garcia, 2005 ^597^ | Self reported anal incontinence 4 months postpartum | 5 | 6 | 33.0 | 55.0 | 0.7 (0.2; 1.8)
N = 41 | Self-reported flatus only incontinence 4 months postpartum | 4 | 3 | 27.0 | 27.0 | 1.0 (0.3;4.1)
| Self-reported stool incontinence 4 months postpartum | 1 | 3 | 4.3 | 16.7 | 0.3 (0.0; 2.3)
Williams, 2006 ^752^ | Defects on Internal sphincter | 4 | 2 | 7.1 | 3.6 | 2.0 (0.4; 10.5)
N = 150 | Defects on external sphincter | 11 | 8 | 19.6 | 14.3 | 1.4 (0.6; 3.2)
Fernando, 2006 ^751^ | Fecal incontinence at 12 months postpartum | 6 | 0 | 24.0 | | 13.0 (0.8; 221.5)
N = 64 | Fecal urgency at 12 months postpartum | 8 | 1 | 32.0 | 3.7 | 8.0 (1.1; 60.3) | 4 (0; 443) | 283 (2; 2195)E
| Flatus incontinence at 12 months postpartum | 4 | 4 | 16.0 | 14.9 | 1.0 (0.3; 3.7)
| Fecal incontinence 6 months postpartum | 6 | 0 | 21.4 | 0.0 | 13.0 (0.8; 221.5)
| Fecal urgency 6 months postpartum | 9 | 2 | 32.1 | 7.1 | 4.5 (1.1; 19.2) | 4 (2; 262) | 250 (4; 1,293)E
| Flatus incontinence 6 months postpartum | 4 | 7 | 14.3 | 25.0 | 0.6 (0.2; 1.8) | 9 (5; -5)
| Cured of anal Incontinence from 6 weeks to 12 months | 4 | 7 | 16.0 | 25.9 | 0.6 (0.2; 1.8) | 10 (5; -5)
Tjandra, 2003 ^753^ | Self-reported fecal incontinence “Success” | 9 | 8 | 75 | 72.7 | 1.0 (0.6; 1.7)
N = 23

Bold - significant difference in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F182 Comparative effectiveness of different techniques to repair anal sphincter (clinical events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CL)
Sample
Fitzpatrick, 2000 ^754^ | Approximation repair: end to end | Primary anal sphincter overlap | Self-reported symptoms of fecal incontinence | 33 | 27 | 58.0 | 49.0 | 1.2 (0.9; 1.7)
N = 112 | | | Continence score >10 | 5 | 2 | 9.0 | 4.0 | 2.5 (0.5; 12.4)
| | | Fecal urgency <5 minutes | 17 | 11 | 30.0 | 20.0 | 1.5 (0.8; 3.0)
| | | Scar only in endoanal ultrasonography | 4 | 6 | 7.0 | 11.0 | 0.6 (0.2; 2.2)
| | | Defect ≤1 quadrant, external anal sphincter | 50 | 43 | 88.0 | 78.0 | 1.1 (0.9; 1.3)
| | | Defect >1 quadrant, external anal sphincter | 3 | 6 | 5.0 | 11.0 | 0.5 (0.1; 1.8)

Table F183 Comparative effectiveness of different techniques to repair anal sphincter (instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcomes | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Fitzpatrick, 2000 ^754^ | Approximation repair: end to end | Primary anal sphincter overlap | Median continence score | 2.0 ± 8.0 | 0.0 ± 8.7 | 0.2 (-0.1; 0.6)
N = 112 | | | Resting pressure (mm/Hg) | 42.0 ± 30.0 | 49.0 ± 34.0 | -0.2 (-0.6; 0.2) | -0.4 (-1.2; 0.3)
| | | Squeeze pressure (mm/Hg) | 66.0 ± 34.7 | 74.0 ± 37.3 | -0.2 (-0.6; 0.1) | -0.3 (-0.8; 0.2)
| | | Squeeze increment (mm/Hg) | 20.0 ± 44.0 | 25.0 ± 34.0 | -0.1 (-0.5; 0.2) | -0.5 (-2.0; 1.0)
| | | Vector symmetry index | 0.6 ± 0.2 | 0.7 ± 0.1 | -0.4 (-0.7; 0.0) | -52.5 (-107.4; 2.5)

Table F184 Comparative effectiveness of end-to-end technique vs. overlapping repair of obstetric anal sphincter lacerations (severity measures an instrumental outcomes)

Outcomes | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Continence score at 3 months ^752^ | 0.0 ± 9.3 | 0.0 ± 9.3 | 0.0 ( -0.4; 0.4)
Resting pressure ^752^ | 44.0 ± 31.3 | 47.0 ± 28.7 | -0.1 (-0.5; 0.3) | -0.2 (-1.0; 0.6)
Increment squeeze pressure ^752^ | 30.0 ± 26.7 | 29.0 ± 35.3 | 0.0 (-0.3; 0.4) | 0.1 (-1.2; 1.4)
Pudendal nerve motor latency - right ^752^ | 1.9 ± 0.4 | 1.9 ± 0.3 | -0.1 (-0.5; 0.3) | -4.6 (-24.1; 14.9)
Pudendal nerve motor latency - left ^752^ | 2.0 ± 0.5 | 1.9 ± 0.3 | 0.1 (-0.3; 0.4) | 2.7 (-16.5; 21.9)
Cleveland Clinic Continence Score ^753^ | 3.0 ± 4.7 | 3.0 ± 4.0 | 0.0 (-0.8; 0.8) | 0.0 (-27.3; 27.3)
Mean Resting pressure - mm/Hg ^753^ | 45.0 ± 23.3 | 50.0 ± 20.7 | -0.2 (-1.0; 0.6) | -0.5 (-2.1; 1.2)
Max squeeze pressure ^753^ | 125.0 ± 40.0 | 130.0 ± 16.0 | -0.2 (-1.0; 0.7) | -0.1 (-0.8; 0.5)

Table F185 Comparative effectiveness of clinical interventions to reduce fecal incontinence after obstetric trauma (clinical events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Dannecke, 2005 ^590^ | Restrictive episiotomy | Liberal episiotomy | Self-reported fecal incontinence 18 months postpartum | 6 | 10 | 19.0 | 24.0 | 0.7 (0.2; 1.7)
N = 146
Hannah, 2004 ^593^ | Planned cesarean delivery | Planned vaginal birth | Fecal incontinence is not a problem at all 2 years postpartum | 3 | 2 | 27.3 | 22.2 | 1.5 (0.3; 9.0)
N = 2,088 | | | Fecal incontinence is a big problem 2 years postpartum | 1 | 3 | 9.1 | 33.3 | 0.3 (0.0; 3.2)
| | | Self-reported flatus incontinence 2 years postpartum | 60 | 53 | 13.1 | 11.5 | 1.1 (0.8; 1.6)
Hannah, 2002 ^592^ | Planned cesarean delivery | Planned vaginal birth | Self-reported fecal incontinence 3 months postpartum | 5 | 9 | 0.8 | 1.5 | 0.6 (0.2; 1.7)
N = 2,088 | | | Self-reported flatus incontinence 3 months postpartum | 66 | 59 | 10.7 | 9.7 | 1.1 (0.8; 1.6)
Fitzpatrick, 2002 ^755^ | Immediate pushing | 60 minute delay prior to the commencement of active pushing. | Self-reported fecal incontinence 3 months postpartum | 23 | 33 | 26.0 | 38.0 | 0.7 (0.4; 1.1)
N = 178 | | | % of normal ultrasound | 14 | 19 | 40.0 | 49.0 | 0.7 (0.4; 1.3)
| | | <1 quad external anal sphincter defect 3 months postpartum ultrasound | 19 | 20 | 54.0 | 51.0 | 0.9 (0.5; 1.6)
| | | >1 quad EAS defect 3 months postpartum ultrasound | 2 | 0 | 6.0 | 0.0 | 4.9 (0.2; 100.4)
Johanson, 1999 ^596^ | Delivery with vacuum extractor | Forceps delivery | Self-reported frequent fecal incontinence | 1 | 1 | 0.3 | 0.3 | 1.1 (0.1; 16.7)
N = 607 | | | Self-reported fecal incontinence, sometimes | 28 | 16 | 9.5 | 5.1 | 1.8 (1.0; 3.3)
Fitzpatrick, 2003 ^756^ | Vacuum assisted delivery | Low-cavity, non-rotational forceps assisted delivery | Fecal urgency <5 minutes | 21 | 19 | 30.4 | 31.1 | 1.0 (0.6; 1.6)
N = 130 | | | Abnormal endoanal ultrasound | 34 | 34 | 49.3 | 55.7 | 1.0 (0.7; 1.4)
| | | Abnormal endoanal ultrasound: >1 quadrant defect | 2 | 2 | 2.9 | 3.3 | 0.5 (0.1; 3.7)
Sultan, 1998 ^757^ | Delivery with vacuum extractor | Forceps delivery. | Anal sphincter defects | 13 | 14 | 48.0 | 82.0 | 1.7 (1.0; 3.1)
N = 44 | | | Anal incontinence | 7 | 3 | 26.0 | 18.0 | 3.5 (1.0; 12.2)
Wiilliams, 2006 ^752^ | Suture material vicryl | Suture material PDS | Defects on Internal sphincter | 6 | 0 | 10.7 | 0.0 | 13.0 (0.7; 225.4)
N = 150 | | | Defects on external sphincter | 12 | 7 | 21.4 | 12.5 | 1.7 (0.7; 4.0)
Sartore, 2004 ^591^ | Mediolateral episiotomy | No episiotomy | % with self-reported anal incontinence | 7 | 5 | 2.8 | 1.9 | 1.47 (0.46; 5)
N = 519

Table F186 Comparative effectiveness of clinical interventions to reduce fecal incontinence after obstetric trauma (severity measures and instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Dannecke, 2005 ^590^ | Restrictive episiotomy | Liberal episiotomy | Anal canal functional length (rest), mm/Hg | 50.0 ± 12.0 | 50.0 ± 10.0 | 0.0 (-0.3; 0.3) | 0.0 (-0.6; 0.6)
N = 176 | | | Anal canal functional length (contraction), mm/Hg) | 42.0 ± 12.0 | 45.0 ± 13.0 | -0.2 (-0.6; 0.1) | -0.5 (-1.3; 0.2)
| | | Anal maximum pressure (rest), mm/Hg | 113. 0 ± 35.0 | 121.0 ± 35.0 | -0.2 (-0.6; 0.1) | -0.2 (-0.5; 0.1)
| | | Anal maximum pressure (contraction), mm/Hg | 143.0 ± 43.0 | 166.0 ± 56.0 | -0.5 (-0.8; -0.1) | -0.3 (-0.5; -0.1)
Fitzpatrick, 2002 ^755^ | Immediate pushing | 60 minute delay, prior to the commencement of active pushing. | Fecal continence scores (median) 3 months postpartum | 3.0 ± 3.3 | 4.0 ± 3.3 | -0.3 (-0.6; 0.0) | -7.5 (-14.9; -0.1)
N = 178 | | | Squeeze pressure (mm/Hg) | 93.0 ± 84.7 | 100.0 ± 49.3 | -0.1 (-0.4; 0.2) | -0.1 (-0.4; 0.2)
| | | Resting pressure (mm/Hg) | 62.0 ± 50.7 | 64.0 ± 50.7 | 0.0 (-0.3; 0.3) | -0.1 (-0.5; 0.4
| | | Squeeze Increment (mm/Hg) | 27.0 ± 69.3 | 31.0 ± 61.3 | -0.1 (-0.4; 0.2) | -0.2 (-1.1; 0.8)
| | | Vector symmetry index | 0.7 ± 0.2 | 0.7 ± 0.2 | -0.1 (-0.4; 0.2) | -17.7 (-60.3; 24.9)
Fitzpatrick, 2003 ^756^ | Vacuum assisted delivery | Low cavity, non-rotational forceps assisted delivery | Fecal incontinence scores | 3.0 ± 6.0 | 3.0 ± 5.3 | 0.0 (-0.3; 0.3) | 0.0 (-11.5; 11.5)
N = 130 | | | Resting pressure (mm/Hg) | 63.0 ± 38.7 | 54.0 ± 41.3 | 0.2 (-0.1; 0.6) | 0.4 (-0.2; 1.1)
| | | Squeeze pressure (mm/Hg) | 96.0 ± 57.3 | 86.0 ± 44.0 | 0.2 (-0.2; 0.5) | 0.2 (-0.2; 0.6)
| | | Squeeze increment (mm/Hg) | 25.0 ± 77.3 | 27.0 ± 42.7 | 0.0 (-0.4; 0.3) | -0.1 (-1.4.; 1.2)
| | | Vector symmetry index | 0.7 ± 0.1 | 0.7 ± 0.1 | 0.0 (-0.3; 0.3) | 0.0 (-48.5; 48.5)
Sultan, 1998 ^757^ | Delivery with vacuum extractor | Forceps delivery | Maximum resting pressure (mm/Hg) | 55.0 ± 15.0 | 60.0 ± 15.0 | -0.3 (-0.9; 0.3) | -0.6 (-1.6; 0.5)
N = 44 | | | Maximum squeeze pressure (mm/Hg) | 38.0 ± 14.0 | 53.0 ± 24.0 | -0.8 (-1.5; -0.2) | -1.6 (-2.8; -0.3)
Williams, 2006 ^752^ | Suture material vicryl | Suture material PDS | Continence score at 3 months | 0.0 ± 9.3 | 0.0 ± 6.7 | 0.0 (-0.4; 0.4)
N = 150 | | | Resting pressure | 43.0 ± 27.3 | 48.0 ± 28.7 | -0.2 (-0.5; 0.2) | -0.4 (-1.1; 0.4)
| | | Increment squeeze pressure | 23.0 ± 31.3 | 30.0 ± 34.7 | -0.2 (-0.6; 0.2) | -0.7 (-1.9; 0.5)
| | | Pudendal nerve motor latency, right | 1.9 ± 0.4 | 1.9 ± 0.3 | -0.2 (-0.5; 0.2) | -9.0 (-28.5; 10.4)
| | | Pudendal nerve motor latency, left | 1.9 ± 0.4 | 2.0 ± 0.5 | -0.1 (-0.4; 0.3) | -3.6 (-22.6; 15.4)

Bold- significant differences in outcomes at 95% confidence level

Table F187 Comparative effectiveness of surgical interventions on fecal incontinence in females (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Faltin, 2005 ^758^ | Clinical and ultrasound examination of the anal sphincter | Clinical examination alone | Self-reported fecal incontinence 3 months postpartum (Wexner scores >0) | 120 | 114 | 33.0 | 32.1 | 1.1 (0.9; 1.3)
N = 752 | | | Self-reported fecal incontinence 1 year postpartum (Wexner scores >0) | 86 | 91 | 25.1 | 26.6 | 0.9 (0.7; 1.2)
| | | Self-reported daily flatus incontinence 3 months postpartum | 7 | 15 | 1.9 | 4.2 | 0.5 (0.2; 1.1)
| | | Self-reported daily flatus incontinence 1 year postpartum | 2 | 3 | 0.6 | 0.9 | 0.7 (0.1; 4.0)
| | | Daily fecal urgency 3 months postpartum | 4 | 3 | 1.1 | 0.9 | 1.3 (0.3; 5.9)
| | | Daily fecal urgency 1 year postpartum | 2 | 1 | 0.6 | 0.3 | 2.0 (0.2; 22.0)
Thakar, 2002 ^599^ | Subtotal hysterectomy | Total hysterectomy | Incontinence in flatus 12 months after operation | 2 | 2 | 1.5 | 1.4 | 1.1 (0.2: 7.7)
N = 279

Table F188 Comparative effectiveness of surgical interventions on fecal continence in females (events)

Author | Active | Control | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Deen, 1994 ^759^ | Abdominal resection rectopexy and pelvic floor repair | Perineal rectosigmoidectomy and pelvic floor repair. | Self-reported fecal continence (cured) | 4 | 4 | 40.0 | 40.0 | 1.0 ( 0.3; 2.9)
N = 20
Sayfan, 1990 ^760^ | Marlex mesh posterior rectopexy alone | Sigmoidectomy combined with a sutured posterior rectopexy | Self-reported restored fecal continence | 9 | 6 | 56.3 | 46.2 | 1.2 (0.6; 2.5)
N = 29
Deen, 1993 ^762^ | Postanal repair alone | Anterior levatorplasty and sphincter plication alone | Self-reported fecal continence | 4 | 4 | 33.3 | 33.3 | 1.0 (0.3; 3.1)
N = 36 | Total pelvic floor repair | | | 9 | 4 | 75.0 | 33.3 | 2.3 (0.9; 5.3)
Davis, 2004 ^763^ | Anterior overlapping sphincter repair using interrupted non-absorbable sutures and levatorplasty using absorbable sutures. | Anterior overlapping sphincter repair plus visual or auditory biofeedback with dual-balloon pressure system during pelvic floor exercise 2 times/day | Complete fecal continence at 12 months | 1 | 1 | 5.0 | 5.6 | 0.9 (0.1; 13.4)
N = 38 | | | Proportion of patients with composite fecal continence scores >9 with fecal continence score <9 (0 - no incontinence to 20 - complete incontinence) | 10 | 13 | 47.8 | 71.4 | 0.7 (0.4; 1.2)
Van Tets, 1998 ^765^ | Postanal repair with levator ani and plicated of the external anal sphincter | Total pelvic floor repair with a combination of postanal repair, anterior Ievatorptasty, and anterior sphincter plication | Complete incontinence, continuing fecal leakage | 6 | 6 | 54.5 | 66.7 | 0.8(0.4;1.7)
N = 20

Table F189 Comparative effectiveness of surgical interventions of progression of fecal incontinence in females (events)

Author | Active | Control | Outcome | Number of Active Cases | Number of Control Cases | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Yoshioka, 1999 ^761^ | Gluteus maximus transposition (without electrical stimulation) | Total pelvic floor repair | Number of patients with no improvement in fecal urgency | 3 | 5 | 25.0 | 41.7 | 0.6 (0.2; 2.0)
N = 24 | | | Number of patients failing to achieve full continence | 4 | 5 | 33.3 | 41.7 | 0.8 (0.3; 2.3)
Faltin, 2005 ^758^ | Clinical and ultrasound examination of the anal sphincter | Clinical examination alone | Self-reported severe fecal incontinence 3 months postpartum (Wexner scores >4) | 12 | 31 | 3.3 | 8.7 | 0.4 (0.2; 0.7) | 19 (14; 45) | 54 (22; 69)A
N = 752 | | | Self-reported severe fecal incontinence 1 year postpartum (Wexner scores >4) | 11 | 23 | 3.2 | 6.7 | 0.5 (0.2; 1.0) | 29 (20; 454) | 35 (2; 51)A
| | | Daily lifestyle alteration due to fecal incontinence 3 months postpartum | 2 | 5 | 0.5 | 1.4 | 0.4 (0.1; 2.0)
| | | Daily lifestyle alteration due to fecal incontinence 1 year postpartum | 3 | 6 | 0.9 | 1.8 | 0.5 (0.1; 2.0)
Deen, 1993 ^762^ | Postanal repair alone | Anterior levatorplasty and sphincter plication alone | Manometry: presence of reactoanal inhibitory reflex | 11 | 10 | 91.7 | 83.3 | 1.1 (0.8; 1.5)
N = 24 | Total pelvic floor repair | | Manometry: presence of reactoanal inhibitory reflex | 12 | 10 | 100.0 | 83.3 | 1.2 (0.9; 1.6)
Davis, 2004 ^763^ | Anterior overlapping sphincter repair using interrupted non-absorbable sutures and levatorplasty using absorbable sutures. | Anterior overlapping sphincter repair plus visual or auditory biofeedback with dualballoon pressure system during pelvic floor exercise 2 times/day | Symptomatic improvement in fecal incontinence | 13 | 17 | 64.7 | 92.8 | 0.7 (0.5; 1.0) | 4 (2; 33) | 281 (30; 474)A
N = 38

Bold- significant difference in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient = 1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control -rate of the outcome in the active group);

A - avoided; E - excessive events

Table F190 Comparative effectiveness of surgical interventions on self-reported severity of fecal incontinence in females

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Yoshioka, 1999 ^761^ | Gluteus maximus transposition (without electrical stimulation) | Total pelvic floor repair | Fecal Incontinence score | 7.7 ± 6.1 | 6.6 ± 4.5 | 0.2 (-0.6; 1.0) | 3.1 (-9.0; 15.3)
N = 24
Davis, 2004 ^763^ | Anterior overlapping sphincter repair using interrupted non-absorbable sutures and levatorplasty using absorbable sutures. | Anterior overlapping sphincter repair plus visual or auditory biofeedback with dual-balloon pressure system during pelvic floor exercise 2 times/day | Continence Grading Scale Score (0 - no incontinence to 20 - complete incontinence) | 9.7 ± 4.7 | 8.4 ± 5.1 | 0.3 (-0.4; 0.9) | 3.1 (-4.5; 10.7)
N = 38 | Direct sphincter repair and levatorplasty with pelvic floor muscle exercise training and biofeedback therapy | Direct sphincter repair and levatorplasty | Continence Grading Scale Score (n) | 8.4 ± 5.1 | 9.7 ± 4.7 | -0.3 (-0.9; 0.4) | -2.7 (-9.3; 3.9)
| | | Patient satisfaction visual analogue score (n) | 6.3 ± 3.4 | 6.4 ± 3.4 | 0.0 (-0.6; 0.6) | -0.1 (-10.2; 9.9)
| | | Quality of life scores, lifestyle | 3.4 ± 0.8 | 2.8 ± 0.9 | 0.7 (0.0; 1.3) | 23.4 (0.2; 46.6)
| | | Fecal continence scores (range: 0–20) | 7.4 ± 4.6 | 9.1 ± 4.9 | -0.4 (-1.0; 0.3) | -4.0 (-11.1; 3.0)
| | | Patient satisfaction visual analogue scores range: 0–10) | 8.0 ± 2.5 | 6.4 ± 2.9 | 0.6 (-0.1; 1.2) | 9.1 (-1.0; 19.3)

Table F191 Comparative effectiveness of surgical interventions on progression of fecal incontinence (instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Deen, 1994 ^759^ | Abdominal resection rectopexy and pelvic floor repair | Perineal rectosigmoidectomy and pelvic floor repair. | Maximum resting pressure, cm/H20 | 63.3 ± 28.7 | 51.2 ± 29.6 | 0.4 (-0.5; 1.3) | 0.8 (-0.9; 2.5)
N = 20 | | | Maximum squeeze pressure, cm/H20 | 97.6 ± 29.1 | 103.0 ± 49.2 | -0.1 (-1.0; 0.7) | -0.1 (-1.0; 0.7)
Sayfan, 1990 ^760^ | Marlex mesh posterior rectopexy alone | Sigmoidectomy combined with a sutured posterior rectopexy | Resting anal pressure, H20 | 69.0 ± 23.3 | 86.0 ± 32.7 | -0.6 (-1.4; 0.1) | -0.7 (-1.6; 0.2)
N = 29 | | | Maximal squeeze pressure, c/ H2O | 134. 0 ± 86.7 | 137.0 ± 112.0 | 0.0 (-0.8; 0.7) | 0.0 (-0.6; 0.5)
| | | Rectal emptying | 58.0 ± 17.3 | 41.0 ± 19.3 | 0.9 (0.2; 1.7) | 2.3 (0.4; 4.2)
Yoshioka, 1999 ^761^ | Gluteus maximus transposition (without electrical stimulation) | Total pelvic floor repair | Change from baseline in length of high pressure zone, cm | -2.6 ± 0.9 | -2.0 ± 0.7 | -0.7 (-1.6; 0.1) | 37.2 (78.7; -4.3)
N = 24 | | | Change from baseline in maximum squeeze pressure, cm/H2O | -92.7 ± 25.8 | -94.5 ± 50.3 | 0.0 (-0.8; 0.8) | 0.0 (0.8; -0.9)
| | | Mucosal electro sensitivity, mA | 10.8 ± 5.8 | 12.7 ± 5.9 | -0.3 (-1.1; 0.5) | -2.6 (-8.9; 3.8)
| | | Change in maximum resting anal pressure, cm/H2O | -60.3 ± 16.5 | -63.4 ± 32.2 | 0.1 (-0.7; 0.9) | -0.2 (1.1; -1.5)
Deen, 1993 ^762^ | Total pelvic floor repair | Anterior levatorplasty and sphincter plication alone | Manometry: maximum squeeze pressure, cm/H20 | 131.0 ± 10.0 | 141.0 ± 17.0 | -0.7 (-1.5; 0.1) | -0.5 (-1.1; 0.1)
N = 24
Davis, 2004 ^763^ | Anterior overlapping sphincter repair using interrupted non-absorbable sutures and levatorplasty using absorbable sutures. | Anterior overlapping sphincter repair plus visual or auditory biofeedback with dual-balloon pressure system during pelvic floor exercise 2 times/day | Resting anal pressures mean, cm H2O | 65.9 ± 19.5 | 77.3 ± 14.8 | -0.7 (-1.3; 0.0) | -0.8 (-1.7; 0.0)
N = 38 | | | Squeeze anal pressures, mean, cm/H2O | 105.4 ± 34.7 | 129.5 ± 32.1 | -0.7 (-1.4; -0.1) | -0.6 (-1.1; 0.0)
Deen, 1995 ^764^ | Adjuvant internal anal sphincter plication in pelvic floor repair | Pelvic floor repair alone | Maximum resting pressure, cm/H20 | 63.2 ± 18.5 | 86.9 ± 31.5 | -0.9 (-1.7; -0.2) | -1.1 (-1.9; -0.2)
N = 33 | | | Maximum squeezing pressure. cm/H20 | 92.0 ± 72.0 | 140.0 ± 98.0 | -0.6 (-1.3; 0.1) | -0.4 (-0.9; 0.1)
| | | Improvement in anal mucosal electro sensitivity | 2.2 ± 8.7 | 0.5 ± 6.6 | 0.2 (-0.5; 0.9) | 47.5 (-98.7; 193.8)
| | | Rectal capacity | 189.0 ± 38.7 | 207.2 ± 60.5 | -0.4 (-1.1; 0.3) | -0.2 (-0.5; 0.2)
Davis, 2004 ^763^ | Direct sphincter repair and levatorplasty with pelvic floor muscle exercise training and biofeedback therapy | Direct sphincter repair and levatorplasty. | Resting anal pressures, mean, cm/H2O | 77.3 ± 14.8 | 65.9 ± 19.5 | 0.7 (0.0; 1.3) | 1.0 (0.0; 2.0)
N = 38 | | | Squeeze anal pressures, mean, cm/H2O | 129.5 ± 32.1 | 105.4 ± 34.7 | 0.7 (0.1; 1.4) | 0.7 (0.1; 1.3)

Bold- significant difference in outcomes at 95% confidence level

Table F192 Comparative effectiveness of radiotherapy for prostate cancer on fecal incontinence

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Peeters, 2006 ^766^ | Three-dimensional conformal radiotherapy 68Gy | Three-dimensional conformal radiotherapy 78Gy | Fecal incontinence as use of incontinence pads for rectal loss of blood, mucus, or stools (requiring the use of pads more than twice a week) at 4 years | 21 | 40 | 6.5 | 12.2 | 0.5 (0.3; 0.9) | 18 (12; 69) | 57 (15; 83)A
N = 669 | | | Incontinence pad use at 5 years | 40 | 51 | 12.3 | 15.5 | 0.9 (0.7; 1.1)
Fransson, 2001 ^686^ | Radiotherapy with a total dose of 4.8 Gy (range, 62.3–70.0 Gy) given for 5 days a week, 2 grays (Gy)/fraction. | Active surveillance | Use of sanitary shields for stool leakage | 5 | 2 | 8.6 | 4.1 | 2.1 (0.4; 10.2)
N = 166
Little, 2003 ^676^ | Radiation with a four-field box technique to a dose of 70Gy arm | Radiation with three-dimensional conformal techniques to generate a six-field boost plan of a total dose of 78Gy | Self-reported fecal continence | 89 | 91 | 82.4 | 88.3 | 0.9 (0.8; 1.0)
N = 301

Bold- significant difference in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome in 1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group;

A - avoided; E - excessive events

Table F193 The changes in self-reported fecal incontinence after radiotherapy of prostate cancer in 166 males compared to active surveillance

Sample | Active treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Fransson, 2001 ^686^ | Radiotherapy with a total dose of 4.8Gy (range, 62.3–70.0Gy) given for 5 days a week, 2grays (Gy) per fraction. | Self-reported stool leakage 0 - “no problem/very good function” and 10 - “many problems/very bad function” | 0.8 ± 1.5 | 0.3 ± 1.3 | 0.3 (0.0; 0.7) | 115.9 (-11.4; 243.1)

Table F194 Bowel management in 87 patients with spinal cord injury (29% females) and symptoms of neurogenic bowel dysfunction ^767^

Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Cleveland Clinic constipation scoring system | 10.3 ± 4.4 | 13.2 ± 3.4 | -0.7 (-1.2; -0.3) | -5.6 (-8.9; -2.3)
St Mark's fecal incontinence grading system | 5 ± 4.6 | 7.3 ± 4.0 | -0.5 (-1.0; -0.1) | -7.3 (-13.2; -1.5)
Neurogenic bowel dysfunction score | 10.4 ± 6.8 | 13.3 ± 6.4 | -0.4 (-0.9; 0.0) | -3.3 (-6.5; -0.1)
American Society of Colon and Rectal Surgeons fecal incontinence score | 3 ± 0.7 | 2.8 ± 0.8 | 0.3 (-0.2; 0.7) | 9.5 (-5.6; 24.6)
Influence of fecal incontinence on daily activities | 4.5 ± 3.2 | 4.1 ± 2.8 | 0.1 (-0.3; 0.6) | 3.3 (-7.0; 13.5)
Number of episodes where due to fecal incontinence it was necessary to change clothes | 0.3 ± 0.6 | 0.3 ± 0.7 | 0.0 (-0.4; 0.4) | 0.0 (-140.2; 140.2)

Bold - significant differences in outcomes at 95% confidence level

Table F195 Comparative effectiveness of surgical interventions on fecal incontinence in patients with hemorrhoid disease (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Galizia, 2000 ^771^ | Complete excision of three hemorrhoids (Milligan-Morgan technique) and lateral internal sphincterotomy up to the dentate line, in left haemorrhoidectomy wound. | Complete excision of three hemorrhoids (Milligan-Morgan technique) | Self-reported fecal incontinence | 1 | 0 | 4.5 | 0.1 | 2.7 (0.1; 63.6)
N = 42
48% female
Konsten, 2000 ^769^ | Hemorrhoidectomy with no retractor (Miller method) | Hemorrhoidectomy with forced anal dilation. | Self-reported fecal incontinence to liquid | 1 | 1 | 2.5 | 3.0 | 1.3 (0.1; 19.4)
N = 118 | | | Self-reported fecal incontinence to solid stool | 4 | 8 | 10.0 | 18.0 | 0.6 (0.2; 1.9)
42% female | Hemorrhoidectomy with forced anal dilation and after treatment for 6 month original Lord's procedure. | Hemorrhoidectomy with forced anal dilation. | Self-reported fecal incontinence to liquid | 4 | 1 | 10.0 | 3.0 | 4.5 (0.5; 38.7)
| | | Self-reported fecal incontinence to solid stool | 6 | 8 | 15.0 | 18.0 | 0.8 (0.3; 2.2)
Hetzer, 2002 ^768^ | Stapled hemorrhoidectomy (Longo technique) with circular anal dilatator introduced to reduce the prolapse of the anoderm and parts of the anal mucous membrane. | Excision hemorrhoidectomy (Ferguson technique). | Self reported fecal continence | 20 | 20 | 100.0 | 100.0
N = 40
28% female
Jayne, 2002 ^770^ | Ligasure haemorrhoidectomy applying repeated diathermy forceps across the hemorrhoid with associated skin tag. Completion of coagulation was signaled by the feedback sensors, and haemorrhoidal tissue was excised along the line of coagulum. | Open diathermy haemorrhoidectomy | Self-reported fecal incontinence fecal continence | 20 | 20 | 100.0 | 100.0
N = 40
47% female
Filingeri, 2004 ^773^ | Submucosal hemorrhoidectomy with radiofrequency bistoury | Conventional Parks' hemorrhoidectomy | Self-reported fecal continence | 51 | 51 | 100.0 | 100.0
N = 102
53% female
Lawes, 2004 ^772^ | Ligasure haemorrhoidectomy with controlled quantity of bipolar diathermy current to tissue ensuring the complete coagulation of blood vessels | Standard diathermy haemorrhoidectomy | Self-reported fecal continence | 12 | 11 | 66.7 | 68.8 | 1.0 (0.6; 1.5)
N = 34 | | | Self-reported incontinence to liquid | 0 | 1 | 0.0 | 6.3 | 0.3 (0.0; 6.8)
50% female
Johannsson, 2006 ^774^ | Open (Milligan- Morgan) haemorrhoidectomy | Closed (Ferguson) haemorrhoidectomy with wounds sutures without tension | Fecal incontinence-loose feces | 8 | 1 | 7.0 | 0.9 | 7.7 (1.0; 60.2)
N = 250 | | | Fecal incontinence-solid feces | 1 | 0 | 0.9 | 0.0 | 2.9 (0.1; 69.7)
54% female
Khan, 2001 ^775^ | Excisional Hemorrhoidectomy with the ultrasonically activated scalpel (Harmonic Scalpel) | Closed excisional hemorrhoidectomy assisted by electrocautery | Self-reported fecal continence | 14 | 16 | 100 | 100
N = 30
37% female
Ho, 2000 ^777^ | Conventional open diathermy hemorrhoidectomy | Stapled hemorrhoidectomy | Incontinence to liquids and gas | 2 | 0 | 3.2 | 0.1 | 4.6 (0.2; 93.9)
N=119
52% female

Table F196 Comparative effectiveness of surgical interventions on progression of fecal incontinence in patients with hemorrhoid disease (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI)
Sample
Galizia, 2000 ^771^ | Complete excision of three hemorrhoids (Milligan-Morgan technique) and lateral internal sphincterotomy up to the dentate line, in left haemorrhoidectomy wound. | Complete excision of three hemorrhoids (Milligan-Morgan technique) | Rectoanal inhibitory reflex, presence | 22 | 20 | 100.0 | 100.0
N = 42
48% female
Jayne, 2002 ^770^ | Ligasure haemorrhoidectomy applying repeated diathermy forceps across the hemorrhoid with associated skin tag. Completion of coagulation was signaled by the feedback sensors, and haemorrhoidal tissue was excised along the line of coagulum. | Open diathermy haemorrhoidectomy | Self-reported increase in fecal incontinence | 3 | 5 | 15.0 | 25.0 | 0.6 (0.2; 2.2)
N = 40
47% female
Johannsson, 2006 ^774^ | Open (Milligan- Morgan) haemorrhoidectomy | Closed (Ferguson) haemorrhoidectomy with wounds sutures without tension | Self-reported improvement in anal continence | 29 | 26 | 25.2 | 23.6 | 1.1 (0.7; 1.7)
N = 250
54% female

Table F197 Comparative effectiveness of surgical interventions on fecal incontinence in patients with hemorrhoid disease (self-reported severity scores and instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Khan, 2001 ^775^ | Excisional hemorrhoidectomy with the ultrasonically activated scalpel (Harmonic Scalpel) | Closed excisional hemorrhoidectomy assisted by electrocautery | Self-reported general health (SF-36) | 79.0 ± 18.7 | 74.0 ± 16.0 | 0.3 (-0.4; 1.0) | 0.4 (-0.6; 1.4)
N = 30
37% female
Galizia, 2000 ^771^ | Complete excision of three hemorrhoids (Milligan-Morgan technique) and lateral internal sphincterotomy up to the dentate line, in left haemorrhoidectomy wound. | Complete excision of three hemorrhoids (Milligan-Morgan technique) | Resting pressures (mm/Hg): maximal | 89.0 ± 11.3 | 139.4 ± 19.7 | -3.2 (-4.1; -2.3) | -2.3 (-2.9; -1.6)
N = 42 | | | Resting pressures (mm/Hg): mean | 46.1 ± 8.0 | 71.1 ± 10.3 | -2.7 (-3.6; -1.9) | -3.8 (-5.0; -2.6)
48% female | | | Squeeze pressures (mm/Hg): maximal | 217.5 ± 50.7 | 267.0 ± 55.5 | -0.9 (-1.6; -0.3) | -0.3 (-0.6; -0.1)
| | | Squeeze pressures (mm/Hg): mean | 96.2 ± 29.1 | 120.8 ± 37.1 | -0.7 (-1.4; -0.1) | -0.6 (-1.1; -0.1)
van Tets, 1997 ^776^ | Closed hemorrhoidectomy performed intra-anally using the Parks' anal retractor | Closed hemorrhoidectomy performed perineally without the use of a retractor | Resting anal pressure | 84.0 ± 30.0 | 93.0 ± 36.2 | -0.3 (-0.9; 0.4) | -0.3 (-1.0; 0.4)
N = 40 | | | Squeeze pressure | 90.0 ± 54.1 | 102.0 ± 67.5 | -0.2 (-0.8; 0.4) | -0.2 (-0.8; 0.4)
50% female
Johannsson, 2006 ^774^ | Open (Milligan- Morgan) haemorrhoidectomy | Closed (Ferguson) haemorrhoidectomy with wounds sutures without tension | Miller scores | 1.6 ± 8.3 | 1.0 ± 7.3 | 0.1 (-0.2; 0.3) | 8.1 (-18.6; 34.8)
N = 250
54% female
Ho, 2000 ^777^ | Conventional open diathermy hemorrhoidectomy | Stapled hemorrhoidectomy | Mean anal resting pressure (mm/Hg) | 52.7±63.0 | 59.9 ± 36.2 | -0.1(-0.5 0.2) | -0.2(-0.8; 0.4)
N=119 | | | Max anal resting pressure, mm/Hg | 181.2±246.5 | 222.9 ±1 67.6 | -0.2(-0.6; 0.2) | -0.1(-0.2; 0.1)
52% females | | | Internal sphincter thickness, mm | 2.2 ± 1.6 | 2.6 ± 2.3 | -0.2(-0.6; 0.2) | -7.9(-21.8; 5.9)
| | | External sphincter thickness, mm | 10.7 ± 4.7 | 11.0 ± 3.0 | -0.1(-0.4; 0.3) | -0.7(-4.0; 2.6)

Bold- significant difference in outcomes at 95% confidence level

Table F198 Comparative effectiveness of clinical interventions in patients with colo-rectal diseases to reduce risk of fecal incontinence (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relat ive Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributa ble Events/1,000 Treated
Sample
Schouten, 1991 ^778^ | Incision, drainage and fistulectomy with primary partial internal sphincterectomy | Incision and drainage alone with secondary partial internal sphincterectomy | Recurrence or persistence rate of fistula | 1 | 14 | 2.9 | 40.6 | 0.1 (0.0; 0.5) | 3 (2; 5) | 377A
N = 70 | | | Anal function disturbances: control of flatus and soiling at 1 year | 14 | 7 | 39.4 | 21.4 | 1.9 (0.9; 4.1)
83% female
Singer, 2005 ^779^ | Tisseel-VH fibrin sealant intra-adhesive cefoxitin 100mg surgical closure of primary opening | Tisseel-VH fibrin sealant intra-adhesive cefoxitin 100mg | Self-reported fecal continence | 24 | 26 | 100.0 | 100.0
N = 75 | Tisseel-VH fibrin sealant surgical closure of primary opening | | | 25 | 26 | 100.0 | 100.0
32% female
Libertiny, 2002 ^780^ | Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day for 8 weeks. | Lateral sphincterotomy | Self-reported flatus incontinence | 0 | 1 | 0.1 | 2.8 | 0.3 (0.0; 7.9)
N = 82
48% female
Mishra, 2005 ^781^ | Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day | Lateral sphincterotomy | Self-reported flatus incontinence | 0 | 3 | 0.1 | 15.0 | 0.1 (0.0; 2.6)
N = 40
50% female
Oettle, 1997 ^782^ | Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day | Lateral sphincterotomy | Self-reported fecal continence | 12 | 12 | 100.0 | 100.0
N = 24
50% female
Richard, 2000 ^783^ | Application of 0.25 percent nitroglycerin tid to perianal area | Internal sphincterotomy | Self-reported minor fecal incontinence | 7 | 3 | 15.9 | 7.9 | 2.0 (0.6; 7.3)
N = 82 | Application of 0.25 percent nitroglycerin tid to perianal area 3 times/day | Internal sphincterotomy | Self-reported fecal continence | 27 | 30 | 61.4 | 78.9 | 0.8 (0.6; 1.0)
55% female
Evans, 2001 ^784^ | Glyceryl trinitrate application 0.2% paste to perianal area 3 times/day for 8 weeks. | Lateral sphincterotomy next available operating list | Self-reported minor FI | 0 | 2 | 0.1 | 6.5 | 0.2 (0.0; 3.7)
N = 65
65% female
Peeters, 2005 ^674^ | Radiotherapy with total dose of 25Gy administered in 5 fractions over 5 to 7 days before total mesorectal excision | Total mesorectal excision | FI during a day | 190 | 111 | 62.0 | 38.0 | 1.6 (1.4; 1.9) | 4 (7; 3) | 240E
N = 597 | | | FI during a night | 98 | 49 | 32.0 | 17.0 | 1.9 (1.4; 2.6) | 7 (15; 4) | 150E
38% female | | | Use of pads for Fecal Incontinence | 171 | 96 | 56.0 | 33.0 | 1.7 (1.4; 2.1) | 4 (8; 3) | 230E
| | | Complete fecal continent (FI at baseline) | 116 | 180 | 38.0 | 62.0 | 0.6 (0.5; 0.7) | 4 (3; 6) | 240A
| | | Always fecal continent (FI at baseline) | 43 | 15 | 14.0 | 5.0 | 2.7 (1.5; 4.8) | 11 (5; 36) | 90E
Peeters, 2005 ^674^ | Radiotherapy with total dose of 25Gy was administered with 5Gy fractions to rectum, perirectal tissues, anal sphincters, and regional lymph nodes before low anterior resection of rectal cancer | Low anterior resection of rectal cancer without pre operative radiotherapy. | Self-reported fecal incontinence | 12 | 11 | 57.0 | 26.0 | 2.2 (1.2; 4.2) | 3 (1; 20) | 310E
N = 64 | | | Self-reported gas incontinence | 15 | 20 | 71.0 | 46.0 | 1.5 (1.0; 2.3) | 4 (2; 226) | 250E
50% female | | | Self-reported soiling | 8 | 7 | 38.0 | 16.0 | 2.3 (1.0; 5.6)
| | | Rectoanal inhibitory reflex. | 17 | 36 | 81.0 | 83.7 | 1.0 (0.8; 1.2)
Dahlberg, 1998 ^787^ | Preoperative high-dose radiotherapy with 25Gy given in 5 fractions for 5–7 days followed by anterior resection of rectal cancer | Anterior resection of rectal cancer alone | Fecal urgency, toilet dependence | 25 | 5 | 30.0 | 6.0 | 5.2 (2.1; 12.9) | 4 (1; 15) | 240E
N = 171 | | | Bowel empting difficulties | 44 | 31 | 52.0 | 36.0 | 1.5 (1.0; 2.1) | 6 (3; 74) | 160E
51% female | | | Incontinence of gas | 57 | 44 | 68.0 | 51.0 | 1.3 (1.0; 1.7) | 6 (3; 49) | 170
| | | Incontinence of loose stool | 42 | 21 | 50.0 | 24.0 | 2.1 (1.3; 3.2) | 4 (2; 12) | 260E
| | | Incontinence of solid stool | 12 | 3 | 14.0 | 3.0 | 4.1 (1.2; 14.2) | 9 (3; 157) | 110E
| | | Fecal nocturnal leakage | 12 | 7 | 14.0 | 8.0 | 1.8 (0.7; 4.3)
| | | Use of pad for FI | 41 | 19 | 49.0 | 22.0 | 2.2 (1.4; 3.5) | 4 (2; 11) | 270E
| | | Ability to release flatus without stool | 73 | 82 | 87.0 | 94.0 | 0.9 (0.8; 1.0)
| | | Excellent operation with respect to bowel function | 12 | 28 | 14.0 | 32.0 | 0.4 (0.2; 0.8) | 6 (4; 17) | 180A
| | | Restriction in social life because of fecal incontinence | 25 | 9 | 30.0 | 10.0 | 2.9 (1.4; 5.8) | 5 (2; 23) | 200E
Lundby, 2005 ^789^ N=494 | Postoperative radiotherapy after anterior resection | Anterior resection alone | Loose or liquid stool | 9 | 3 | 3.7 | 1.2 | 3.1 (0.8; 11.2)
| | | Fecal incontinence | 9 | 1 | 3.7 | 0.4 | 9.2 (1.2; 72.2) | 30(4; 1411) | 33E
| | | Use of pad for fecal incontinence | 7 | 0 | 2.9 | 0.0 | 15.4 (0.9; 267.6)
Pollack, 2006 ^675^ | Abdominal rectal resection with preoperative radiotherapy | Abdominal rectal resection without preoperative radiotherapy | Fecal incontinence | 12 | 11 | 2.01 | 1.36 | 1.48 (0.66, 3.34)
N = 1,406
56% female
Followup 180

Bold- significant difference in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome inn1 patient = 1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F199 Comparative effectiveness of clinical interventions in patients with rectal diseases to reduce risk of fecal incontinence (self-reported severity scores and instrumental outcomes)

Author | Active | Control | Outcome | Mean ± STD After Active Treatment | Mean STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Zimmerman, 2003 ^785^ | Parks retractor during fistula repair | Scott retractor during fistula repair | Mean anal resting pressure | 52.4 ± 26.4 | 65.5 ± 18.6 | 0.6 (-1.3; 0.2) | -0.9 (-2.0; 0.2)
N = 30 | | | Maximal anal squeeze pressure | 172.9 ± 67.9 | 144.5 ± 57.6 | 0.5 (-0.3; 1.2) | 0.3 (-0.2; 0.8)
30% female | | | Rockwood fecal continence severity index. | 12.7 ± 12.9 | 7.5 ± 9.6 | 0.5 (-0.3; 1.2) | 6.1 (-3.6; 15.7)
Ho, 2005 ^786^ | Dermal island flap anoplasty with cutaneous advancement flap into the rectum | Conventional treatment: lay open fistulotomy or seton insertion | Self-reported fecal incontinence scores | 1.3 ± 4.1 | 1.3 ± 3.2 | 0.0 (-0.9; 0.9) | 0.0 (-67.4; 67.4)
N = 20
96% female
Richard, 2000 ^783^ | Application of 0.25% nitroglycerin tid to perianal area 3 times/day | Internal sphincterotomy | Fecal incontinence Wexner scores | 0.5 ± 1.3 | 0.2 ± 0.6 | 0.3 (-0.1; 0.7) | 144.7 (-73.5; 362.9)
N = 82
59% female
Comparative effectiveness of clinical interventions in patients with rectal cancer (self-reported severity scores)
Allgayer, 2005 ^788^ | Postoperative irradiation (total dose 50.4±/2.0Gy) applied in split doses (1.8Gy, 5/week). Intensive daily pelvic floor exercise with biofeedback intra-anal electromyogram electrode device | Intensive daily pelvic floor exercise with biofeedback intra-anal electromyogram electrode device | Modified Cleveland Incontinence Score at 3 weeks | 9.3 ± 2.5 | 11.5 ± 2.6 | -0.9 (-1.3; -0.4) | -7.5 (-11.2; -3.8)
N = 95 | | | Modified Cleveland Incontinence Score at 1 year | 8.1 ± 3.6 | 10.5 ± 4.4 | -0.6 (-1.0; -0.2) | -5.6 (-9.6; -1.7)
42% female
Dahlberg, 1998 ^787^ | Preoperative high-dose radiotherapy with 25Gy given in 5 fractions for 5–7 days followed by anterior resection of rectal cancer | Anterior resection of rectal cancer alone | Fecal urgency, deferring time, minutes | 5.0 ± 76.7 | 10.0 ± 193.3 | 0.0 (-0.3; 0.3) | -0.3 (-3.3; 2.7)
N = 171
51% female

Bold- significant difference in outcomes at 95% confidence level

Table F200 Comparative effectiveness of surgical interventions on fecal incontinence in patients with rectal prolapse (events)

Author | Active | Control | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95% CI) | Number Needed to Treat (95% CI) | Number of attributable Events/1,00 0 Treated
Sample
Luukkonen, 1992 ^790^ | Posterior sutured abdominal rectopexy combined with sigmoidectomy complete rectal prolapse and end-to-end anastomosis made with a circular stapler | Polyglycolic acid mesh rectopexy without sigmoidectomy for complete rectal prolapse anterior rectal wall free | Complete anal continence | 9 | 11 | 27.3 | 73.3 | 0.4 (0.2; 0.7) | 2 (2; 5) | 219A
N = 30 | | | Self-reported incontinence for solid stool (grade 3) | 1 | 1 | 6.7 | 6.7 | 1.0 (0.1; 14.6)
33% female | | | Self-reported incontinence for liquid stool (grade 2) | 1 | 0 | 6.6 | 0.1 | 3.0 (0.1; 68.3)
Racalbuto, 2004 ^791^ | Stapled prolapsectomy using Longo circular stapler. | Traditional Milligan-Morgan Hemorrhoidecto my with exeresis of the haemorrhoidal piles upon low ligature of each vascular pedicle | Fecal urgency with occasional incontinence to gas and liquid stool (Wexner score 4) | 3 | 3 | 6.0 | 6.0 | 1.0 (0.2; 4.7)
N = 100
44% female
Novell, 1994 ^792^ | Ivalon sponge with sutured rectangle of sponge placed along the length of the sacrum | Sutured rectopexy with sutured rectangle of sponge or sutures alone placed along the length of the sacrum | Self-reported fecal incontinence as fecal soiling or using a pad | 6 | 2 | 19.4 | 6.3 | 3.1 (0.7; 14.2)
N = 63
99% female

Bold- significant differences in outcomes at 95% confidence level;

A - Number of avoided; E - number of excessive events per 1000 treated

Table F201 Effect of surgical procedures on severity of fecal incontinence

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Luukkonen, 1992 ^790^ | Posterior sutured abdominal rectopexy combined with sigmoidectomy complete rectal prolapse and end-to-end anastomosis made with a circular stapler | Polyglycolic acid mesh rectopexy without sigmoidectomy for complete rectal prolapse anterior rectal wall free | Resting anal pressure (mean), cm/H20 | 34.5 ± 11.7 | 30.7 ± 11.5 | 0.3 (-0.4; 1.0) | 1.1 (-1.3; 3.4)
N = 30 | | | Maximal squeeze pressure, cm/H20 | 53.0 ± 20.7 | 49.3 ± 15.1 | 0.2 (-0.5; 0.9) | 0.4 (-1.0; 1.9)
33% female
Racalbuto, 2004 ^791^ | Stapled prolapsectomy using Longo circular stapler. | Traditional Milligan-Morgan Hemorrhoidectomy with exeresis of the haemorrhoidal piles upon low ligature of each vascular pedicle | Mean basal pressure | 82.1 ± 11.5 | 76.1 ± 13.3 | 0.5 (0.1; 0.9) | 0.6 (0.1; 1.2)
N = 100 | | | Mean maximal squeeze pressure | 101.0 ± 16.7 | 95.0 ± 17.3 | 0.4 (0.0; 0.7) | 0.4 (0.0; 0.8)
44% female
Solomon, 2002 ^793^ | Laparoscopic rectopexy | Open abdominal rectopexy | Self-reported fecal incontinence scores with visual analog scale | 1.6 ± 6.3 | 2.0 ± 4.7 | -0.1 (-0.7; 0.6) | -3.6 (-35.0; 27.8)
N = 40
50% female
Galili, 1997 ^794^ | Posterior abdominal rectopexy with non-absorbable mesh (Polypropylene, Prolene, Ethicon Ltd) | Posterior abdominal rectopexy with absorbable mesh (Polyglycolic acid, Dexon, Davis & Geck) | Impact on social life (1 - unrestricted social life) | 0.9 ± 0.3 | 0.9 ± 0.4 | 0.1 (-0.6; 0.7) | 6.8 (-65.8; 79.5)
N = 37 | | | Fecal continence scores (as 0 - complete incontinence, 0.5 - incontinence for loose stool only, 1- complete continence) | 0.7 ± 0.3 | 0.8 ± 0.4 | -0.3 (-1.0; 0.3) | -42.2 (-126.8; 42.3)
87% female
Boccasanta, 2006 ^795^ | Altemeier's procedure with levatorplasty using harmonic scalpel and circular stapler | Altemeier's procedure with levatorplasty, monopolar electrocautery and hand sewn anastomosis | Fecal Continence score (Wexner score, ranging from 0 - full continence to 20 - complete incontinence). | 7.9 ± 1.9 | 8.1 ± 1.8 | -0.1 (-0.7; 0.5) | -1.3 (-9.0; 6.3)
N = 40 | | | Resting pressure (mm/Hg) | 34.4 ± 5.5 | 34.2 ± 5.4 | 0.0 (-0.6; 0.7) | 0.1 (-1.7; 1.9)
99% female | | | Squeeze pressure (mm/Hg) | 64.8 ± 12.9 | 65.4 ± 12.3 | 0.0 (-0.7; 0.6) | -0.1 (-1.0; 0.9)
| | | Threshold volume (ml): Distention | 41.9 ± 7.6 | 41.5 ± 7.0 | 0.1 (-0.6; 0.7) | 0.1 (-1.4; 1.6)
| | | Threshold volume (ml): desire to defecate | 64.8 ± 9.9 | 65.1 ± 10.5 | 0.0 (-0.6; 0.6) | 0.0 (-1.0; 0.9)
| | | Sacral reflex latency (millisecond) | 62.9 ± 6.4 | 63.0 ± 6.7 | 0.0 (-0.6; 0.6) | 0.0 (-1.0; 1.0)
Boccasanta, 1998 ^796^ | Laparoscopic stapled Well's rectopexy, perineal physiotherapy, external electric stimulation, and perineal biofeedback | Well's rectopexy by the open technique without division of lateral rectal ligaments, perineal physiotherapy, external electric stimulation, and perineal biofeedback | Self-reported fecal incontinence scores from 0 - complete continence to 6 - complete incontinence. | 9.0 ± 2.0 | 10.0 ± 2.0 | -0.5 (-1.4; 0.4) | -5.0 (-13.9; 3.9)
N = 21 | | | Basal pressure, mm/Hg | 47.2 ± 22.3 | 47.2 ± 46.1 | 0.0 (-0.9; 0.9) | 0.0 (-1.9; 1.9)
95% female | | | Squeezing pressure, mm/Hg | 97.4 ± 9.7 | 98.4 ± 42.2 | 0.0 (-0.9;0.8) | 0.0 (-0.9; 0.9)
| | | Rectal capacity, ml | 170.4 ± 10.1 | 171.4 ± 43.0 | 0.0 (-0.9; 0.8) | 0.0 (-0.5; 0.5)
| | | Rectoanal inhibitory reflex, ml | 17.3 ± 3.2 | 15.3 ± 21.2 | 0.2 (-0.7; 1.0) | 1.0 (-4.8; 6.8)
| | | Threshold volume, ml | 14.9 ± 2.5 | 15.1 ± 9.6 | 0.0 (-0.9; 0.8) | -0.2 (-6.0; 5.6)
| | | Painful reflex to rectal stretching, ml | 30.9 ± 3.6 | 31.9 ± 13.9 | -0.1 (-1.0; 0.8) | -0.4 (-3.1; 2.4)

Bold- significant difference in outcomes at 95% confidence level

Table F202 Comparative effectiveness of surgical interventions on anal sphincter to prevent incidence of fecal incontinence in adults (events)

Author | Active Treatment | Control Treatment | Outcome | Number of Cases After Active Treatment | Number of Cases After Control Treatment | Rate (%) After Active Treatment | Rate (%) After Control Treatment | Relative Risk (95 %C)I | Number Needed to Treat (95% CI) | Number of attributable Events/1,000 Treated (95% CI)
Sample
Parallada, 2004 ^798^ | Surgical: open lateral internal sphincterotomy and mucose closure with chromic catgut. | Chemical: local 0.2 percent isosorbide dinitrate - peasize quantity applied manually at the entrance of the anus, 3 times/day immediately after a warm sitz bath, for 6 weeks. | Self-reported fecal continence | 30 | 33 | 100.0 | 100.0
N = 63 | | | Self-reported absence of fecal soiling | 30 | 33 | 100.0 | 100.0
96% female | | | Self-reported gas incontinence and fecal soiling | 9 | 0 | 30.0 | 0.1 | 20.8 (1.3; 343.3)
Zbar, 2003 ^801^ | Modified cutting seton, which repaired the internal anal sphincter muscle and rerouted the seton through the intersphincteric space. | Conventional cutting seton | Self-reported fecal continence | 18 | 15 | 100.0 | 94.0 | 1.1 (0.9; 1.3)
N = 34
26% female
Wiley, 2004 ^797^ | Closed lateral internal sphincterotomy (Hoffman and Goligher) using a short stab incision and blind division of the internal sphincter guided by the surgeon finger. | Open lateral sphincterotomy (Parks) via a 1cm radial incision with division of the internal sphincter under direct vision. | Self-reported major fecal incontinence | 1 | 2 | 2.6 | 4.9 | 0.5 (0.1; 5.7)
N = 79
54% female
Wong, 2002 ^799^ | Implantation of Acticon trade mark artificial bowel sphincter - solid silicone elastomer device. | Baseline condition | Urge fecal incontinence | 22 | 100 | 20.0 | 89.0 | 0.2 (0.2; 0.3) | 1 (1; 2) | 690 (604; 756)A
N = 112
75% female
Arroyo, 2005 ^800^ | Close lateral internal sphincterotomy | Chemical sphincterotomy with 25 units botulinum toxin injected into the internal sphincter | Self-reported fecal incontinence (<4 in Cleveland Clinic Scoring System) at 2 months | 2 | 2 | 5.0 | 5.0 | 1.0 (0.1; 6.8)
N = 80 | | | Self-reported fecal incontinence (<4 in Cleveland Clinic Scoring System) at 1–3 years | 1 | 0 | 2.5 | 0.1 | 3.0 (0.1; 71.5)
35% female

Bold- significant difference in outcomes at 95% confidence level;

Number needed to treat to have avoided or excessive outcome inn1 patient =1/(rate of the outcome in the control - rate of the outcome in the active group);

Number of attributable events = 1000*(rate of the outcome in the control - rate of the outcome in the active group);

A - avoided; E - excessive events

Table F203 Comparative effectiveness of surgical interventions on anal sphincter to prevent progression of fecal incontinence in adults (self-reported severity scores)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Wiley, 2004 ^797^ | Closed lateral internal sphincterotomy (Hoffman and Goligher) using a short stab incision and blind division of the internal sphincter guided by the surgeon finger. | Open lateral sphincterotomy (Parks) via a 1cm radial incision with division of the internal sphincter under direct vision. | Self-reported fecal continence scores (0 - continence, 20 - complete incontinence) | 1.0 ± 1.1 | 1.0 ± 1.8 | 0.0 (-0.4; 0.4) | 0.0 (-46.5; 46.5)
N = 79
54% female
Wong, 2002 ^799^ | Implantation of Acticon trade mark artificial bowel sphincter - solid silicone elastomer device. | Baseline condition | Self-reported fecal incontinence using Fecal Incontinence Scoring System (FISS), from 0 - complete continence to 120 - complete incontinence. | 48.0 ± 48.0 | 106.0 ± 9.3 | -1.7 (-2.0; -1.4) | -1.6 (-1.9; -1.3)
N = 112
75% female
Osterberg, 2004 ^802^ | Anterior levatorplasty with mobilization of external sphincter | Anal (and vaginal in women) plug electrostimulation of the pelvic floor with stimulation frequency was 25Hz and the duration 1.5 seconds, with a pulse-train interval of 3 seconds. | Self-reported loose stool at 3 months (0 - total continence to 18 - maximum incontinence). | 15.0 ± 13.3 | 11.0 ± 29.3 | 0.2 (-0.3; 0.6) | 1.6 (-2.7; 5.9)
N = 70 | | | Self-reported loose stool at 1 year (0 - total continence to 18 - maximum incontinence). | 14.0 ± 14.7 | 10.0 ± 29.3 | 0.2 (-0.3; 0.6) | 1.7 (-3.0; 6.4)
90% female | | | Self-reported solid fecal incontinence stool at 3 months (0 - total continence to 18 - maximum incontinence). | 32.0 ± 27.3 | 25.0 ± 50.0 | 0.2 (-0.3; 0.6) | 0.7 (-1.2; 2.6)
| | | Self-reported solid fecal incontinence stool at 1 year (0 - total continence to 18 - maximum incontinence). | 30.0 ± 12.7 | 27.0 ± 40.7 | 0.1 (-0.4; 0.6) | 0.4 (-1.4; 2.1)
| | | Fecal Incontinence score (0–18) at 1 year | 6.0 ± 5.3 | 8.0 ± 4.0 | -0.4 (-0.9; 0.0) | -5.3 (-11.2; 0.6)
Tjandra, 2004 ^803^ | PTP injection into intersphincteric space and internal anal sphincter with guidance by endoanal ultrasound | PTP injection into intersphincteric space and internal anal sphincter without guidance by endoanal ultrasound | Wexner's continence score at 3 months | 7.0 ± 3.3 | 9.5 ± 3.0 | -0.8 (-1.2; -0.3) | -8.3 (-13.0; -3.6)
N = 82 | | | Visual analog quality of life scale at 3 months | 9.0 ± 0.7 | 9.0 ± 0.7 | 0.0 (-0.4; 0.4) | 0.0 (-4.8; 4.8)
78% female | | | Fecal incontinence quality of life index at 6 months | 3.7 ± 0.4 | 3.1 ± 0.8 | 0.9 (0.5; 1.4) | 29.3 (14.7; 44.0)
O'Brien, 2004 ^804^ | Placement of the artificial bowel sphincter activated at 6 weeks after surgery. | Usual supportive care: physiotherapy, pelvic floor exercise, dietary advice. | Cleveland Clinic Scoring for fecal incontinence | 4.8 ± 4.0 | 14.3 ± 4.6 | -2.2 (-3.6; -0.8) | -15.4 (-25.0; -5.8)
N = 14 | | | American Medical Systems quality of life questionnaire specialized on Fecal incontinence | 82.7 ± 14.0 | 54.7 ± 26.0 | 1.3 (0.2; 2.5) | 2.5 (0.3; 4.6)
93% female

Bold- significant difference in outcomes at 95% confidence level

Table F204 Comparative effectiveness of surgical interventions on anal sphincter to prevent perceived progression of fecal incontinence in adults (self-reported severity scores and instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Parellada, 2004 ^798^ | Surgical: open lateral internal sphincterotomy and mucose closure with chromic catgut. | Chemical: local 0.2% isosorbide dinitrate - peasize quantity applied manually at the entrance of the anus, 3 times/day immediately after a warm sitz bath, for 6 weeks. | Maximum resting pressure (cm/H2O) | 48.0 ± 16.0 | 56.0 ± 48.0 | -0.2 (-0.7; 0.3) | -0.4 (-1.3; 0.5)
N = 63 | | | Maximum squeezing pressure (cm/H2O) | 136.0 ± 149.3 | 120.0 ± 160.0 | 0.1 (-0.4; 0.6) | 0.1 (-0.3; 0.5)
96% female | | | Rectal capacity and first sensation: Functional capacity (cm 3 air) | 140.0 ± 213.3 | 120.0 ± 253.3 | 0.1 (-0.4; 0.6) | 0.1 (-0.3; 0.5)
| | | Rectal capacity (cm 3 air) | 230.0 ± 220.0 | 280.0 ± 280.0 | -0.2 (-0.7; 0.3) | -0.1 (-0.2; 0.1)
| | | Rectal capacity and first sensation: slow waves,% | 160.0 ± 0.0 | 14.0 ± 52.0 | | 0.0 (0.0; 0.0)
| | | Rectal capacity and first sensation: ultra-slow waves, % | 30.0 ± 0.0 | 3.0 ± 11.0 | | 0.0 (0.0; 0.0)
Osterberg, 2004 ^802^ | Anterior levatorplasty with mobilization of external sphincter | Anal (and vaginal in women) plug electrostimulation of the pelvic floor with stimulation frequency was 25Hz and the duration 1.5 seconds, with a pulse-train interval of 3 seconds. | Maximum resting pressure (cm/H2O) at 1 year | 40.0 ± 32.7 | 49.5 ± 38.7 | -0.3 (-0.7; 0.2) | -0.5 (-1.5; 0.4)
N = 70 | | | Maximum squeeze pressure (cm/H2O) at 1 year | 59.0 ± 60.7 | 75.5 ± 62.0 | -0.3 (-0.7; 0.2) | -0.4 (-1.0; 0.3)
90% female | | | Resting pressure (cm/H2O) at 1 year | 44.0 ± 44.0 | 35.0 ± 32.7 | 0.2 (-0.2; 0.7) | 0.7 (-0.7; 2.0)
| | | Squeeze pressure (cmH2O) | 90.0 ± 60.0 | 89.0 ± 66.7 | 0.0 (-0.5; 0.5) | 0.0 (-0.5; 0.5)
| | | High-pressure zone (cm) at 1 year | 3.0 ± 0.7 | 3.0 ± 0.7 | 0.0 (-0.5; 0.5) | 0.0 (-15.6; 15.6)
| | | Rectoanal inhibitory reflex (cm/H2O) | 20.0 ± 20.0 | 25.0 ± 6.7 | -0.3 (-0.8; 0.1) | -1.3 (-3.2; 0.5)
| | | Rectal compliance (ml per 40 cm/H2O) at 1 year | 160.0 ± 56.7 | 159.5 ± 74.0 | 0.0 (-0.5; 0.5) | 0.0 (-0.3; 0.3)
Tjandra, 2004 ^803^ | PTP injection into intersphincteric space and internal anal sphincter with guidance by endoanal ultrasound | PTP injection into intersphincteric space and internal anal sphincter without guidance by endoanal ultrasound | Maximum resting pressure (mm/Hg) at 6 months | 38.0 ± 12.4 | 35.0 ± 6.5 | 0.3 (-0.1; 0.7) | 0.9 (-0.4; 2.1)
N = 82 | | | Maximum squeeze pressure (mm/Hg) at 6 months | 116.0 ± 21.7 | 121.0 ± 21.2 | -0.2 (-0.7; 0.2) | -0.2 (-0.6; 0.2)
78% female
Zbar, 2003 ^801^ | Modified cutting seton, which repaired the internal anal sphincter muscle and rerouted the seton through the intersphincteric space. | Conventional cutting seton | Mean resting anal pressure, mm/Hg | 106.1 ± 3.8 | 80.0 ± 16.1 | 2.3 (1.4; 3.2) | 2.9 (1.8; 4.0)
N = 34 | | Conventional cutting seton | high pressure zone, length, mm | 21.1 ± 6.0 | 17.0 ± 5.0 | 0.7 (0.0; 1.4) | 4.3 (0.2; 8.4)
26% female | | | Asymmetry, % | 29.9 ± 1.0 | 39.0 ± 7.1 | -1.9 (-2.7;-1.0) | 4.7 (-6.8; -2.7)
| | | Mean resting vector volume | 37,800.7 ± 8,010.0 | 25,099.9 ± 8,112.9 | 1.6 (0.8; 2.4) | 0.0 (0.0; 0.0)
| | | Mean squeeze pressure, mm/Hg | 120.7 ± 20.0 | 104.0 ± 9.1 | 1.1 (0.3; 1.8) | 1.0 (0.3; 1.7)
| | | Squeeze manometric parameters: high pressure zone length, mm | 26.1 ± 11.0 | 21.3 ± 5.0 | 0.6 (-0.1; 1.2) | 2.6 (-0.6; 5.8)
| | | Squeeze manometric parameters: asymmetry, % | 31.1 ± 5.0 | 34.0 ± 11.1 | -0.3 (-1.0; 0.3) | 1.0 (-3.0; 1.0)
| | | Squeeze manometric parameters: mean squeeze vector volume | 50,224.2 ± 17,001.4 | 53,806.7 ± 9,108.8 | -0.3 (-0.9; 0.4) | 0.0 (0.0; 0.0)

Bold- significant difference in outcomes at 95% confidence level

Table F205 Fecal continence and pad use of 1, 85 patients operated on for chronic ulcerative colitis at 1, 5, 10, 15, and 20 years of followup ^824^

Years of followup | 1 Year | 5 Years | 10 Years | 15 Years | 20 Years
Fecal continence daytime, % | 71 | 70 | 60 | 59 | 59
Fecal continence night time, % | 43 | 40 | 33 | 25 | 32
Pad use, % | 34 | 29 | 31 | 43 | 50

Table F206 Table F206. Functional outcome of 1,885 patients operated on for chronic ulcerative colitis by time period of operation ^824^

| 1981-1985 | 1986-1990 | 1991-1995 | 1996-2000
Number of patients | 431 | 557 | 470 | 427
Mean age at surgery (years) | 31·2 | 33·7 | 35·4 | 36·3
Mean followup (years) | 16·8 | 13·1 | 8·8 | 5·0
Mean stool frequency after ileal pouch-anal anastomosis
Per day | 6·4 | 6·1 | 6·2 | 6·4
Per night | 2·1 | 2·0 | 2·0 | 2·1
Incontinence during day (%)
Never | 57 | 54 | 64 | 70
Occasional | 31 | 35 | 26 | 21
Frequent | 11 | 11 | 10 | 9
Incontinence during night (%)
Never | 30 | 29 | 34 | 37
Occasional | 48 | 48 | 48 | 41
Frequent | 21 | 23 | 18 | 22
Stool consistency (% of patients)
Liquid | 12 | 11 | 12 | 12
Semi liquid | 70 | 72 | 70 | 69
Solid | 18 | 17 | 17 | 19
Can distinguish gas from stool (%) | 77 | 74 | 67 | 67
Pad use (%) | 46 | 44 | 39 | 44
Medication use (%) | 50 | 45 | 43 | 51

Table F207 Comparative effectiveness of surgical interventions (diversion) on fecal incontinence in adults (self-reported severity scores)

Author | Active Treatment | Control Treatment | Outcome | Mean ± STD After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% )CI) | % Change from Control (95% CI)
Sample
Furst, 2003 ^814^ | 5cm colonic J-pouch constructed with a linear stapler | 8cm coloplasty pouch sutures horizontally with minimal extension effect. | Number of fecal urgency episodes | 3.5 ± 2.3 | 2.0 ± 2.8 | 0.6 (0.0; 1.2) | 29.3 (-2.4; 61.0)
N = 40 | | | Self-reported number of straining episodes | 4.5 ± 2.8 | 5.0 ± 1.5 | -0.2 (-0.8; 0.4) | -4.5 (-16.9; 8.0)
32% female
Hallbook, 1996 ^808^ | Low anterior resection with total mesorectal excision with straight anastomosis 6 to 8cm in length. | Low anterior resection with total mesorectal excision colonic J pouch anastomosis 6 to 8cm in length. | Composite score of incontinence, 0–18 | 5.0 ± 2.7 | 2.0 ± 2.2 | 1.2 (0.8; 1.7) | 60.9 (39.2; 82.7)
N = 100
45% female
Sailer, 2002 ^816^ | Total mesorectal excision and coloanal J pouch anastomosis by folding the descending colon to the form of a ‘J’, 5 ± 6cm in length. | Total mesorectal excision and straight anastomosis with descending colon anastomosed in end-to-end fashion to the anal canal. | European Organization for Research and Treatment of Cancer, Defecation or stoma scores, 100-poor quality | 23.0 ± 21.0 | 26.0 ± 19.0 | -0.1 (-0.6; 0.3) | -0.6 (-2.5; 1.3)
N = 64 | | | Disease-specific scale (EORTC QLQ-CR38) scales: 0–36 (perfect continence) | 32.0 ± 6.0 | 32.0 ± 3.0 | 0.0 (-0.5; 0.5) | 0.0 (-1.5; 1.5)
38% female | | | Urge to defecate, 0–36 (perfect continence) | 1.9 ± 0.2 | 2.0 ± 0.1 | -0.6 (-1.1; -0.1) | -31.6 (-56.7; -6.5)
| | | Fecal incontinence, 0–36 (perfect continence) | 4.8 ± 1.9 | 4.8 ± 1.5 | 0.0 (-0.5; 0.5) | 0.0 (-10.2; 10.2)
| | | Anal incontinence to gas, 0–36 (perfect continence) | 5.3 ± 1.7 | 5.2 ± 1.4 | 0.1 (-0.4; 0.6) | 1.2 (-8.2; 10.7)
Ho, 2001 ^806^ | Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Standardized ultralow anterior resection with straight coloanal anastomosis, the descending colon was anastomosed to the anorectal stump | Fecal continence Wexner scale from 0 - continence to 24 - complete incontinence. | 0.4 ± 0.3 | 0.1 ± 0.1 | 1.3 (0.5; 2.0) | 912.5 (389.0; 1,436.1)
N = 42
60% female
Ho, 2002 ^809^ | Standardized total mesorectal excision with at least 2 cm of distal tumor clearance. J-pouch was constructed from descending colon 6cm in length using an Autosuture ILA 75 linear cutting stapler. | Standardized total mesorectal excision with at least 2cm of distal tumor clearance. Coloplasty pouch was anastomosed to stapled anorectal stump. | Self-reported fecal continence scores | 1.3 ± 2.7 | 3.2 ± 8.0 | -0.3 (-0.7; 0.1) | -10.0 (-23.2; 3.1)
N = 88 | | | Fecal incontinence specific quality of life scoring: lifestyle | 3.5 ± 1.3 | 3.0 ± 2.0 | 0.3 (-0.1; 0.7) | 9.9 (-4.1; 23.9)
40% female
Furst, 2002 ^818^ | The standardized total mesorectal excision with preaortal lymph node dissection, autonomic nerve preservation, and short (5cm) colonic J-pouch anastomosis. | The standardized total mesorectal excision with preaortal lymph node dissection, autonomic nerve preservation, and straight coloanal anastomosis. | Number of fecal urgency episodes | 2.6 ± 1.7 | 3.6 ± 1.2 | -0.7 (-1.2; -0.2) | -19.2 (-32.3; -6.2)
N = 74 | | | Number of incomplete evacuations | 4.3 ± 1.3 | 5.0 ± 1.2 | -0.6 (-1.1; -0.1) | -12.2 (-21.6; -2.9)
26% female | | | Number of straining episodes | 4.8 ± 1.5 | 3.0 ± 1.4 | 1.3 (0.8; 1.8) | 41.8 (25.1; 58.5)
Park, 2005 ^825^ | Ultralow anterior resection including upper sphincter excision colonic J-pouch anastomosis with a temporary diverting-loop ileostomy | Ultralow anterior resection including upper sphincter excision with a straight anastomosis and temporary diverting-loop ileostomy. | Fecal Incontinence Severity Index (FISI) | 18.6 ± 2.0 | 27.7 ± 2.0 | -4.6 (-5.6; -3.5) | -16.4 (-20.3; -12.6)
N = 50 | | | Fecal Incontinence Quality of Life (FIQL) scale, lifestyle | 3.4 ± 1.0 | 2.7 ± 1.0 | 0.7 (0.1; 1.3) | 26.2 (4.8; 47.6)
22% female
Machado, 2005 ^810^ | Low anterior resection and total mesorectal excision with a colonic J-pouch anastomosis | Low anterior resection and total mesorectal excision with a colonic J-pouch or a side-to-end anastomosis. | Combined functional bowel rank scores | 33.0 ± 6.0 | 37.6 ± 9.6 | -0.6 (-1.1; -0.1) | -1.5 (-2.8; -0.3)
N = 71 | | | Fecal incontinence scores (0–18) | 5.0 ± 1.3 | 6.0 ± 1.3 | -0.8 (-1.2; -0.3) | -12.5 (-20.5; -4.5)
22% female
Laurent, 2005 ^811^ | Total mesorectal excision and hand sewn colonic J-pouch-anal anastomosis (6cm) | Total mesorectal excision and stapled colonic J-pouch-anal anastomosis (6cm) using PI-30 stapling instrument | Number of stools/night | 0.0 ± 0.0 | 0.3 ± 0.1 | | 0.0 (0.0; 0.0)
N = 37 | | | Fecal continence
19% female | | | Cleveland Clinic Fecal Incontinence Score | 0.6 ± 3.6 | 1.0 ± 5.3 | -0.1 (-0.7; 0.6) | -8.6 (-74.4; 57.1)
Patients with ulcerative colitis
Reilly, 1997 ^820^ | Abdominal colectomy excising anal transition zone and hand sewing the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Abdominal colectomy preserving anal transition zone and double stapling the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Number of stools at night | 1.0 ± 1.0 | 2.0 ± 2.0 | -0.6 (-1.3; 0.1) | -31.0 (-66.6; 4.6)
N = 41 | | | Quality of life scores: 1-severely restricted performance to 5- improved performance. | 3.6 ± 1.3 | 3.2 ± 1.6 | 0.3 (-0.4; 1.0) | 8.5 (-13.3; 30.3)
34% female
Oresland, 1988 ^823^ | Anal balloon dilatation with step-wise increasing pressure (5–80cm/H20), distention ~60 seconds for 50–60 minutes. | Sphincter training with visual feedback for 50–60 minutes daily. | Self-reported number of bowel evacuations at 1 month | 7.1 ± 1.7 | 7.0 ± 2.3 | 0.0 (-0.6; 0.7) | 0.7 (-8.4; 9.8)
N = 40 | | | Self-reported number of bowel evacuations at 6 months | 4.9 ± 1.6 | 5.4 ± 1.8 | -0.3 (-0.9; 0.3) | -5.4 (-17.3; 6.4)
50% female
Patients with sphincteric trauma
Hasegawa, 2000 ^815^ | Fecal diversion with defunctioning stoma (closed at 4 months after surgery) for sphincter repair with standard overlapping technique | Sphincter repair with standard overlapping technique with no stoma | Cleveland Clinic Scoring System (0 - perfect continence to 20 - complete incontinence). | 7.8 ± 5.5 | 9.6 ± 6.8 | -0.3 (-1.0; 0.5) | -3.0 (-10.9; 4.9)
N = 27
96% female

Bold- significant difference in outcomes at 95% confidence level

Table F208 Comparative effectiveness of surgical interventions (diversion) on fecal incontinence in adults (instrumental outcomes)

Author | Active Treatment | Control Treatment | Outcome | Mean ± After Active Treatment | Mean ± STD After Control Treatment | Mean Difference (95% CI) | % Change from Control (95% CI)
Sample
Furst, 2003 ^814^ | 5cm colonic J-pouch constructed with a linear stapler | 8cm coloplasty pouch sutures horizontally with minimal extension effect. | Resting pressure, mm/Hg | 45.0 ± 9.0 | 46.0 ± 15.0 | -0.1 (-0.7; 0.5) | -0.2 (-1.5; 1.2)
N = 40 | | | Squeeze pressure, mm/Hg | 219.0 ± 100.0 | 216.0 ± 86.0 | 0.0 (-0.6; 0.7) | 0.0 (-0.3; 0.3)
32% female | | | Rectal threshold volume, ml | 46.0 ± 13.0 | 36.0 ± 28.0 | 0.5 (-0.2; 1.1) | 1.3 (-0.5; 3.0)
| | | Maximum rectal volume, ml | 89.0 ± 18.0 | 77.0 ± 21.0 | 0.6 (0.0; 1.2) | 0.8 (0.0; 1.6)
Johnston, 1996 ^821^ | Duplicated (J) pelvic ileal reservoirs in restorative proctocolectomy constructed with 30cm of ileum | Quadruplicated (W) reservoir pelvic ileal reservoirs in restorative proctocolectomy, constructed with 30cm of ileum | Maximum resting anal pressures | 58.0 ± 21.3 | 57.0 ± 4.7 | 0.1 (-0.4; 0.6) | 0.1 (-0.8; 1.0)
N = 60 | Duplicated (J) pelvic ileal reservoirs in restorative proctocolectomy constructed with 40cm of ileum | Quadruplicated (W) reservoir pelvic ileal reservoirs in restorative proctocolectomy, constructed with 40cm of ileum | Maximum resting anal pressure, mmH20 | 71.0 ± 11.3 | 73.0 ± 5.3 | -0.2 (-0.7; 0.3) | -0.3 (-1.0; 0.4)
57% female
Selvaggi, 2000 ^822^ | Ileal pouch-anal anastomosis including total colectomy, total rectal excision, and two-limb J reservoir | Ileal pouch-anal anastomosis including total colectomy, total rectal excision, and four-limb W reservoir | Maximum tolerated anal volume, ml | 292.3 ± 68.8 | 334.2 ± 79.7 | -0.6 (-1.4; 0.3) | -0.2 (-0.4; 0.1)
N = 24 | | | Maximum anal resting pressure, mm/Hg | 64.7 ± 16.5 | 64.8 ± 16.4 | 0.0 (-0.8; 0.8) | 0.0 (-1.2; 1.2)
58% female | | | Maximum voluntary contraction, mm/Hg | 159.1 ± 37.3 | 159.6 ± 29.8 | 0.0 (-0.8; 0.8) | 0.0 (-0.5; 0.5)
Hasegawa, 2000 ^815^ | Fecal diversion with defunctioning stoma (closed at 4 months after surgery) for sphincter repair with standard overlapping technique | Sphincter repair with standard overlapping technique with no stoma | Maximum resting pressure, H20 | 67.3 ± 28.9 | 71.3 ± 12.1 | -0.2 (-0.9; 0.6) | -0.3 (-1.3; 0.8)
N = 27 | | | Maximum squeezing pressure, H20 | 106.4 ± 29.9 | 100.7 ± 24.1 | 0.2 (-0.5; 1.0) | 0.2 (-0.5; 1.0)
96% female
Sailer, 2002 ^816^ | Total mesorectal excision and coloanal J pouch anastomosis by folding the descending colon to the form of a ‘J’, 5 ± 6cm in length. | Total mesorectal excision and straight anastomosis with descending colon anastomosed in end-to-end fashion to the anal canal. | Resting anal pressure anal pressure (mm/Hg) | 55.0 ± 23.0 | 68.0 ± 36.0 | -0.4 (-0.9; 0.1) | -0.6 (-1.4; 0.1)
N = 64 | | | Squeeze pressure (mm/Hg) | 116.0 ± 47.0 | 109.0 ± 74.0 | 0.1 (-0.4; 0.6) | 0.1 (-0.3; 0.6)
38% female | | | Rectal compliance (ml/mm/Hg) | 3.1 ± 1.4 | 3.1 ± 1.8 | 0.0 (-0.5; 0.5) | 0.0 (-15.8; 15.8)
Ho, 2001 ^806^ | Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Standardized ultra-low anterior resection with straight coloanal anastomosis, the descending colon was anastomosed to the anorectal stump | Change from baseline in mean resting anal pressure (mm/Hg) | 23.7 ± 7.8 | 16.5 ± 8.3 | 0.9 (0.2; 1.6) | 5.4 (1.2; 9.6)
N = 42 | | | Change from baseline in maximum anal squeeze pressure (mm/Hg) | 80.7 ± 35.0 | 102.4 ± 31.7 | -0.7 (-1.3; 0.0) | -0.6 (-1.3; 0.0)
60% female | | | Change from baseline in rectal volume of initial sensation: barostat phasic program (ml) | 24.8 ± 14.8 | 13.5 ± 23.8 | 0.6 (-0.1; 1.2) | 4.1 (-0.9; 9.2)
| | | Change from baseline in rectal compliance: barostat (ml/mm/Hg) | -7.1 ± 5.9 | -14.0 ± 6.2 | 1.1 (0.4; 1.9) | -8.1 (-3.0; -13.3)
| | | Change from baseline in rectosphincteric inhibitory reflex, % | 50.0 | 52.6 | | 0.0 (0.0; 0.0)
Ho, 2002 ^817^ | Standardized ultra-low anterior resection with J pouch anastomosis by folding the descending colon to the form of a ‘J’, 6cm in length | Standardized ultra-low anterior resection with straight coloanal anastomosis. | Mean resting anal pressure, mm/Hg | 31.1 ± 15.2 | 32.3 ± 9.8 | -0.1 (-1.2; 1.0) | -0.3 (-3.8; 3.2)
N = 12 | | Descending colon was anastomosed to the anorectal stump | Maximum anal squeeze pressure, mm/Hg | 182.0 ± 87.0 | 159.0 ± 73.7 | 0.3 (-0.9; 1.4) | 0.2 (-0.5; 0.9)
17% female | | | Volume of initial rectal urge, ml | 42.7 ± 76.9 | 30.3 ± 56.6 | 0.2 (-1.0; 1.3) | 0.6 (-3.1; 4.4)
| | | Maximum tolerable rectal volume, ml | 51.3 ± 118.3 | 43.0 ± 46.3 | 0.1 (-1.0; 1.2) | 0.2 (-2.4; 2.8)
| | | Rectal compliance, ml/mm/Hg | 1.8 ± 1.7 | 1.2 ± 2.2 | 0.3 (-0.8; 1.4) | 25.3 (-69.6; 120.3)
Ho, 2002 ^809^ | Standardized total mesorectal excision with at least 2cm of distal tumor clearance. J-pouch was constructed from descending colon 6cm in length using an Autosuture ILA 75 linear cutting stapler. | Standardized total mesorectal excision with at least 2cm of distal tumor clearance. | Fecal urge: stool deferment time (minutes) | 16.1 ± 17.2 | 16.3 ± 23.2 | 0.0 (-0.4; 0.4) | -0.1 (-2.6; 2.5)
N = 88 | | Coloplasty pouch was anastomosed to stapled anorectal stump. | Mean resting anal pressure (mm/Hg) | 50.4 ± 29.8 | 46.0 ± 33.8 | 0.1 (-0.3; 0.6) | 0.3 (-0.6; 1.2)
40% female | | | Maximum anal squeeze pressure (mm Hg) | 119.5 ± 58.3 | 122.2 ± 85.5 | 0.0 (-0.5; 0.4) | 0.0 (-0.4; 0.3)
| | | Rectal volume of initial sensation (ml) | 59.7 ± 72.9 | 32.6 ± 75.6 | 0.4 (-0.1; 0.8) | 1.1 (-0.2; 2.4)
| | | Maximum tolerable rectal volume (ml) | 108.3 ± 87.5 | 123.1 ± 214.8 | -0.1 (-0.5; 0.3) | -0.1 (-0.4; 0.3)
| | | Rectal compliance | 1.7 ± 2.7 | 3.1 ± 8.0 | -0.2 (-0.7; 0.2) | -7.6 (-21.1; 5.9)
| | | Internal anal sphincter thickness (mm) | 2.6 ± 11.9 | 2.3 ± 1.3 | 0.0 (-0.4; 0.5) | 1.5 (-16.6; 19.7)
| | | External anal sphincter thickness (mm) | 7.7 ± 5.3 | 9.8 ± 6.6 | -0.3 (-0.8; 0.1) | -3.6 (-7.9; 0.7)
Furst, 2002 ^818^ | The standardized total mesorectal excision with preaortal lymph node dissection, autonomic nerve preservation, and short (5cm) colonic J-pouch anastomosis. | The standardized total mesorectal excision with preaortal lymph node dissection, autonomic nerve preservation, and straight coloanal anastomosis. | Resting anal pressure, mm/Hg | 57.0 ± 23.0 | 57.0 ± 17.0 | 0.0 (-0.5; 0.5) | 0.0 (-0.8; 0.8)
N = 74 | | | Squeeze pressure, mm/Hg | 181.0 ± 65.0 | 215.0 ± 71.0 | -0.5 (-1.0; 0.0) | -0.2 (-0.4; 0.0)
26% female | | | Neorectal sensation, ml | 40.0 ± 20.0 | 33.0 ± 20.0 | 0.4 (-0.1; 0.8) | 1.1 (-0.3; 2.5)
| | | Maximal neorectal volume, ml | 107.0 ± 42.0 | 120.0 ± 60.0 | -0.3 (-0.7; 0.2) | -0.2 (-0.6; 0.2)
Machado, 2005 ^810^ | Low anterior resection and total mesorectal excision with a colonic J-pouch anastomosis | Low anterior resection and total mesorectal excision with a colonic J-pouch or a side-to-end anastomosis. | Anal resting pressure, mm/Hg | 42.0 ± 15.3 | 47.0 ± 10.7 | -0.4 (-0.8; 0.1) | -0.8 (-1.8; 0.2)
N = 71 | | | Resting pressure volume, mm Hg2cm | 12,722.0 ± 8,110.7 | 11,342.0 ± 8,508.7 | 0.2 (-0.3; 0.6) | 0.0 (0.0; 0.0)
22% female | | | Anal squeeze pressure, mm/Hg | 106.0 ± 16.7 | 106.0 ± 14.0 | 0.0 (-0.5; 0.5) | 0.0 (-0.4; 0.4)
| | | Squeeze pressure volume, mm Hg2cm | 48,765.0 ± 43,961.3 | 55,650.0 ± 26,946.0 | -0.2 (-0.7; 0.3) | 0.0 (0.0; 0.0)
| | | Maximum neorectal volume, ml | 178.0 ± 32.0 | 126.0 ± 16.0 | 2.0 (1.5; 2.6) | 1.6 (1.2; 2.1)
| | | Neorectal compliance | 4.2 ± 0.8 | 3.2 ± 0.7 | 1.4 (0.8; 1.9) | 42.4 (26.2; 58.6)
| | | Neorectal mobility | 8.0 ± 4.7 | 13.0 ± 4.0 | -1.1 (-1.7; -0.6) | -8.8 (-12.7; -5.0)
| | | Neorectal sensitivity, mm/Hg, initial sensation | 10.0 ± 0.8 | 10.0 ± 3.3 | 0.0 (-0.5; 0.5) | 0.0 (-4.7; 4.7)
| | | Neorectal sensitivity, mm/Hg, urge | 15.0 ± 3.3 | 20.0 ± 0.0 | | 0.0 (0.0; 0.0)
Jiang, 2005 ^819^ | Side-to-end anastomosis after low anterior resection | Colonic J-pouch reconstruction after low anterior resection | maximal resting pressure | 63.3±23.0 | 54.0±24.5 | 0.4(-0.2;1.0) | 0.7(-0.3;1.8)
N=44 | Side-to-end anastomosis after low anterior resection | Colonic J-pouch reconstruction after low anterior resection | maximal contraction pressure | 207.1±104.3 | 148.5±66.6 | 0.7(0.1;1.3) | 0.5(0.1;0.8)
48% female | Side-to-end anastomosis after low anterior resection | Colonic J-pouch reconstruction after low anterior resection | squeeze pressure | 143.8±95.0 | 94.4±58.8 | 0.6(0.0;1.2) | 0.7(0.0;1.3)
| Side-to-end anastomosis after low anterior resection | Colonic J-pouch reconstruction after low anterior resection | Continence | 1.3±1.0 | 1.3±1.0 | 0.0(-0.6;0.6) | 0.0(-43.5;43.5)
Patients with ulcerative colitis
Reilly, 1997 ^820^ | Abdominal colectomy excising anal transition zone and hand sewing the pouch to the anal canal (Ileal Pouch- Anal Anastomosis) | Abdominal colectomy preserving anal transition zone and double stapling the pouch to the anal canal (Ileal Pouch-Anal Anastomosis) | Maximum resting pressure (mm/Hg) | 49.4 ± 18.5 | 78.3 ± 24.5 | -1.3 (-2.1; -0.5) | -1.7 (-2.7; -0.7)
N = 41 | | | Maximum average squeeze pressure (mm/Hg) | 144.0 ± 44.1 | 195.0 ± 63.5 | -0.9 (-1.7; -0.2) | -0.5 (-0.8; -0.1)
34% female | | | Scintigraphic outcome: rest | 116.0 ± 14.3 | 119.0 ± 21.7 | -0.2 (-0.9; 0.5) | -0.1 (-0.7; 0.4)
| | | Scintigraphic outcome: squeeze | 130.0 ± 14.0 | 135.0 ± 19.3 | -0.3 (-1.0; 0.4) | -0.2 (-0.7; 0.3)
| | | Scintigraphic outcome: perineal descent (cm) | 60.0 ± 19.8 | 56.1 ± 18.0 | 0.2 (-0.5; 0.9) | 0.4 (-0.9; 1.6)
| | | Pudendal nerve terminal motor latency (ms), right | 1.9 ± 0.4 | 2.1 ± 1.2 | -0.2 (-0.9; 0.5) | -11.7 (-45.2; 21.8)
| | | Pudendal nerve terminal motor latency (ms), left | 1.9 ± 0.3 | 1.5 ± 0.6 | 0.7 (0.0; 1.4) | 44.7 (-1.8; 91.1)
McKee, 1992 ^813^ | Abdominal rectopexy without zigmoidectomy | Abdominal rectopexy with zigmoidectomy of redundant sigmoid colon and end-to-end anastomosis of colon and rectum made in pelvic brim | Maximum resting anal pressure, mm/Hg | 56.0 ± 13.0 | 40.0 ± 6.0 | 1.6 (0.5; 2.7) | 4.0 (1.3; 6.6)
N = 18 | | | Volume to first sensation, ml | 115.0 ± 32.0 | 143.0 ± 23.0 | -1.0 (-2.0; 0.0) | -0.7 (-1.4; 0.0)
50% female | | | Volume at first leak, ml | 467.0 ± 187.0 | 383.0 ± 185.0 | 0.5 (-0.5; 1.4) | 0.1 (-0.1; 0.4)
| | | Rectal compliance, mm/Hg | 0.2 ± 0.0 | 0.1 ± 0.0 | 7.0 (4.4; 9.6) | 7,000.0 (4,404.6; 9,595.4)
Oresland, 1988 ^823^ | Anal balloon dilatation with step-wise increasing pressure (5–80cm/H20), distention ~60 seconds for 50–60 minutes. | Sphincter training with visual feedback for 50–60 minutes daily. | Resting anal pressure at 1 year, mm/Hg | 56.0 ± 17.0 | 50.0 ± 15.0 | 0.4 (-0.3; 1.0) | 0.8 (-0.5; 2.0)
N = 40
50% female

Bold- significant difference in outcomes at 95% confidence level

Table F209 Evidence tables of diagnostic values of the tests to identify UI and FI in adults

Author, Year, Study Design Level of Evidence Settings | Purpose/Aim of Study | Population: Subject Age, Gender, Race, Ethnicity, Residency | Urodynamic Criteria of UI Definition of Incontinence,
De Muylder, 1992 ^826^ | To evaluate diagnostic value of careful history taking compared to urodynamic evaluation in the diagnosis of female patients with micturition disorders | 408 women with symptoms of UI, 18–78 years old; 202 postmenopausal | ICS. A UD diagnosis of detrusor instability was made if urethrocystometry demonstrated a rise in true detrusor pressure of 15cm water or more. A diagnosis of detrusor instability was also made if a true detrusor rise of more than 5cm water was associated with urethral relaxation and incontinence. Genuine stress incontinence was diagnosed when UI occurred in the absence of a detrusor contraction associated with a rise in intra-abdominal pressure.
Prospective
Observational
II-2
Community
Cundiff, 1997 ^827^ | To characterize historic and clinical parameters in incontinent women to determine the predictive value for urodynamic diagnoses | 535 Women | Occurrence of UI coincident with coughing, sneezing, lifting, and walking was recorded as symptoms of stress urinary incontinence. UI occurring with symptoms of urgency was documented as urge urinary incontinence.
Retrospective | | Mean age: 55.7 | ICS
Observational | | Range:21–95
II-2 | | SD:13.5
Community | | USA
Holtedahl, 2000 ^828^ | To test the usefulness of urodynamic examination in female urinary incontinence | 698 Women | ICS. Leakage was objectively demonstrated in at least one of three ways: visible leakage on coughing during the gynecological examination; a positive 48 hour pad test; or recording of “wet” on a 48 hour frequency/volume chart. UD diagnoses were based on both symptoms and signs: USI when there was a positive stress test with pad weight increase and/or negative maximal urethral closure pressure on coughing; UUI when there was leakage together with motor urgency in the form of detrusor contractions associated with strong desire to void during the filling phase (definite urge), or when there were signs of sensory urgency (such as a subjective maximal capacity <400ml and/or >7 voids/24 hours as shown in the frequency/volume chart brought along by each woman) associated with a history of involuntary leakage together with a strong desire to void (presumed urge); Mixed incontinence if criteria of stress as well as urge were fulfilled. A maximal urethral closing pressure of <25cm/H2O when the patient was resting was interpreted as a sign of urethral insufficiency, although there is no precise cut-off for this condition.
RCT | | Age range: 50–74
I | | Norway
Community
Yalcin, 2004 ^829^ | To assess the accuracy with which a clinical diagnostic algorithm for SUI based on symptoms and signs without including urodynamics predicted the observation of urodynamic SUI and the condition of SUI | 1,455 women | Subjects must have reported a predominant symptom of SUI with a weekly incontinent episode frequency ≥4 in the Phase 2 study and an incontinent episode frequency of ≥7 in 2 Phase 3 studies, in which an episode was defined as easily noticeable urine leakage that wet a pad or clothing and occurred with physical stress such as coughing, sneezing or exercising.
RCT | | Mean age: 51.3 | ICS
I | | Range: 28–81.7
Community | | SD: 11.2
| | USA
Diokno, 1987 ^830^ | To characterize urinary incontinence observed in elderly women and to assess the importance of various parameters used to evaluate urinary incontinence | 200 women | A clinical diagnosis of SUI was made when patient described loss of urine while straining, coughing, bending over, and/or provided objective evidence of stress loss during the physical exam. The loss of urine was clinically considered UUI when it followed an immediate toilet need and nocturia of three or more times was reported.
Prospective | | Mean: 68.5 | ICS
Observational | | Range age: 55–90
II-2 | | SD:8.6
Community | | USA
Diokno, 1990 ^831^ | To determine the value of various tests used to evaluate UI | 456 women | SUI when urine loss was associated with physical exertion.
RCTI | | Age range:60–86 | UUI when urine loss was preceded by an urge to void. A UD diagnosis of incompetent urethral sphincter was made when 1 of the 3 findings was observed: Positive stress test, positive urine loss on stress cystography, positive findings on dynamic urethral profilometry. A diagnosis of competent urethral sphincter made if none of the criteria was satisfied,
Community | | USA
Fitzgerald, 2002 ^832^ | To determine whether scores on two validated urinary incontinence symptom scales predicted eventual urodynamic diagnoses. | 293 women | ICS
CT | | Mean age: 57
II-1 | | Range: 15–87
Community | | USA
Ishiko, 2000 ^833^ | Purpose was to determine whether the urinary incontinence (UI) score is significantly useful in evaluating the clinical status of UI | 198 women | Gaudenz questionnaire partially modified to make it more suitable for a Japanese population was used in this study. It consisted of 15 questions. The answers to each question were assigned a certain number of points, and depending on the answer, included in the stress-score s-s or urge-score u-s. The total s-s and u-s points were added up separately, and a diagnosis was made based on the zones into which each of the scores fell.
CT | | Mean age: 59.1 | ICS
II-1 | | Range: 27–73
Community | | SD: 12.2
| | Japan
Korda, 1987 ^834^ | To evaluate the diagnostic potential of careful history taking | 566 women | ICS
CT | | Mean age: 49
II-1 | | Australia
Community
Kujansuu, 1982 ^835^ | To evaluate the diagnostic accuracy of a scored urological questionnaire in the differential diagnosis of female urinary incontinence | 121 women
Prospective
Observational
II-2
Lagro-janssen, 1991 ^836^ | To assess the diagnostic potential of the patient's medical history in distinguishing between genuine USI, detrusor instability and mixed incontinence in primary care. | 103 women | Incontinence was defined as the involuntary loss of urine twice or more times a month. SUI is the loss of urine during coughing and /or sneezing. UUI is the involuntary loss of urine associated with a strong desire to void.
CT | | Age range: 20–65 | ICS
II-1 | | Netherlands
Community
Niecestro, 1992 ^837^ | To evaluate the ability of stresscath to detect bladder neck incompetence in patients referred for urodynamics | 66 women
Prospective | | USA
Observational
II-2
Community
Ouslander, 1987 ^838^ (Prospective | To compare the clinical presentation of incontinence to diagnoses based on urological and urodynamic evaluation | 135 women | ICS
Observational | | Age >65years
II-2 | | USA
Community
Ramsay, 1993 ^839^ | To define the symptomatology of those patients with detrusor instability, and those with genuine stress incontinence, looking particularly at the severity of urinary incontinence; and to devise a model to more accurately predict the diagnosis from the history alone. | 200 women | Assessment of the severity made by asking 4 questions:
Retrospective | | Mean age: 50.3 | 1 The frequency of urinary leakage (from 0 = never, 1 = <1/monthly, to 6 = ≥6/day); 2 The severity of urinary leakage was assessed by degree of protection required (ranging from 0 = none, 1 = minimal to 5 = continuous sanitary protection); 3 The number of pads used per day; 4 The social restriction their incontinence caused (this was graded 0 = none, 1 = restricted, and 2 = housebound)
Observational | | SD: 11.15
II-2 | | UK
Community
Sand, 1988 ^840^ | To assess the value of history in assessing in establishing the etiology of UI. | 218 women | ICS
CT | | Mean age: 51.8
II-1 | | Range: 18–80
Community | | USA
Sandvik, 1995 ^841^ | To validate simple diagnostic questions concerning female urinary incontinence, for the subsequent implementation in an epidemiological survey. | 785 women | A positive answer to the following question was presumed to be an indication of SUI: “Do you lose urine during sudden physical exertion, lifting, coughing or sneezing?” UUI was presumed to be indicated by a positive answer to the question: “Do you experience such a strong and sudden urge to void that you leak before reaching the toilet?” A positive answer to both questions was registered as mixed incontinence.
CT | | Norway | ICS
II-1
Community
Sunshine ^842^ | Clinical correlation of urodynamic testing in patients with UI | 109
Cantor, 1980 ^843^ | | 214 women
Prospective
Observational
II-2
Weidner, 2001 ^844^ | To determine the predictive value of the symptom of stress urinary incontinence and to evaluate the ability of other factors suggested by a published Agency for Health Care Policy and Research guideline for the discrimination of patients unlikely to require urodynamic testing before surgical management | 950 women | The diagnosis of genuine SUI was made if the subject had the symptom of stress incontinence and had observable leakage produced by stress without concurrently demonstrable detrusor activity during urethrocystometry or urethral profilometry or had a positive result of a direct visualization test immediately after the catheters were removed in the total absence of detrusor instability during previous urethrocystometry. The diagnosis of detrusor instability was made if the subject had a detrusor contraction in association with urgency and leakage. The diagnosis of intrinsic sphincteric deficiency was made on the basis of combined historical, physical, urodynamic, and endoscopic parameters. 16.
Prospective | | Mean age: 55.8 | ICS
Observational | | SD: 13.3
II-2 | | USA
Community
Bergman, 1990 ^845^ | To evaluate prospectively the reliability of the history in the evaluation of female UI | 154 women | Genuine SUI was urodynamically diagnosed when there was visible loss of urine during coughing with pressure equalization between bladder and urethra and in the absence of bladder contraction.
Prospective | | Mean age: 48.7 | ICS
Observational | | France
II-2
Community
Le Coutour, 1990 ^846^ | To assess the diagnostic value of history and UD investigation in female urinary incontinence | 113 women
Prospective | | Mean age: 50
Observational | | Sweden
II-2
Community
Petros, 1992 ^847^ | To test the proposition that the history of urge UI was accurate, by direct observation of events occurring during a provocative hand washing test. | Age range: 35–71 | ICS
Retrospective
Observational
II-2
Community
van Waalwijk van Doorn, 1997 ^848^ | To investigate the usefulness of ambulatory UD to quantify detrusor activity, and develop a parameter to quantify the grade of detrusor over-activity. | 228 women | ICS
Prospective | | Mean age:44.4
Observational | | Range: 9–75
II-2 | | Netherlands
Community
Ficazzola, 1998 ^849^ | To determine the incidence of intrinsic sphincter deficiency and bladder dysfunction, and the contribution of each to incontinence. | 60 men | Detrusor instability was defined as any involuntary bladder contraction of 15 cm. water, according to the International Continence Society, or involuntary contraction of any magnitude associated with urge.
Prospective/Observational | | Mean age: 64.8 | ICS
II-2 | | Range: 48–73
Community | | USA
Ding, 1997 ^850^ | To study the usefulness of lower urinary tract symptoms and postvoid residual urine volume in the diagnosis of voiding dysfunction in elderly men | 126 men
Prospective/Observational
II-2
Porru, 1994 ^851^ | To evaluate bladder behavior in patients with DI correlated incontinence and micturition disorders by performing both a conventional UD investigation and extramural ambulatory monitoring during normal daily activity. | 46 Men and women | ICS
Prospective/Observational | | Mean age: 48.4
II-2 | | Range: 22–80
Community | | Italy
Digesu, 2003 ^852^ | To determine whether the urodynamic diagnosis is useful in the management of women with symptoms of an overactive bladder (OAB). | 4,500 women | Genuine stress incontinence was classified as mild, moderate, and severe if leakage of urine occurred following five, three or one coughs, respectively.
CT | | Mean age: 55.4 | Detrusor instability was diagnosed when detrusor contractions were seen in the presence of urgency or urinary leakage while attempting to inhibit micturition.
I | | Range: 22–73 | ICS
| | UK
Clarke, 1997 ^853^ | To characterize historic and clinical parameters in incontinent women to determine the predictive value for urodynamic diagnoses | 1,000 women
| | Mean age: 53
| | Australia
Kong, 1990 ^854^ | | 269 women
Retrospective/Observational | | Mean age: 77
II-2 | | Range: 59–94
| | UK

Table F210 Recommended questionnaires for UI and lower urinary tract symptoms/overactive bladder (adapted from the Symptom and Quality of Life Committee of the International Consultation on Incontinence) ^855^

Combined symptoms and quality of life impact of UI
Men and women | International Consultation on Incontinence Questionnaire ^856^
Women | Bristol Female Lower Urinary Tract Symptoms Questionnaire-Short Form ^857^
| Stress and Urge Incontinence and Quality of Life Questionnaire (SUIQQ) ^858^
Men | International Continence Society male questionnaire, short form ^859^
Combined symptoms and quality of life of overactive bladder
Men and women | Overactive Bladder Questionnaire ^860^
UI symptoms
Women | Urogenital Distress Inventory ^861^
| Urogenital Distress Inventory-6 ^862^
| Incontinence Severity Index ^863^
| Bristol Female Lower Urinary Tract Symptoms Questionnaire ^864^
Men | International Continence Society male, lower urinary tract symptoms primarily ^865^
| Danish Prostatic Symptom Score, lower urinary tract symptoms primarily ^866^
Quality of life impact of UI
Men and women | Quality of Life in Persons with UI Questionnaire ^867^
| Incontinence Classification System ^868^
Women | King's Health Questionnaire ^869^
| Incontinence Impact Questionnaire ^870^
| Incontinence Impact Questionnaire -7 ^862^
| UI Severity Score (UISS) ^871,^ ^872^
| CONTILIFE—Urinary Incontinence-specific Measure of Quality of Life ^873^
Men | None

Table F211 Questionnaires with rigorous validity, reliability and responsiveness highly recommended by the Symptom and Quality of Life Committee of the International Consultation on Incontinence ^855^

[underlined: International Consultation on Incontinence Questionnaire ^856^]
Consists of four questions and numeric scales:
1 How often do you leak urine? (0–5); never - all the time; 2 How much urine do you usually leak? (0–6); none - large amount; 3 Overall, how much does leaking urine interfere with your everyday life? (0–10); not at all - a great deal; 4 When does urine leak? Multiple choices.
ICIQ score is the sum of questions 1–3.

[underlined: Bristol Female Lower Urinary Tract Symptoms Questionnaire-short form ^857^]
BFLUTS questionnaire symptom items: numbers, labels, and response categories
Question | Symptom | Response Categories
1 +P | Frequency (times daily) | 1–6, 7–8, 9–10, 11–12, 13+
2 +P | Nocturia | 0, 1, 2, 3, 4+
3 +P | Urgency | Never, occasionally, sometimes, most of the time, all of the time
4 +P | Urge incontinence | Never, occasionally, sometimes, most of the time, all of the time
5 +P | Bladder pain | Never, occasionally, sometimes, most of the time, all of the time
6 +P | Frequency incontinence | Never, ≤1/week, 2–3/week, 1/day, several times a day
7 +P | Stress incontinence | Never, occasionally, sometimes, most of the time, all of the time
8 +P | Unpredictable miscellaneous incontinence | Never, occasionally, sometimes, most of the time, all of the time
9 | Volume of leakage | No leakage, drops/pants damp, dribble/pants wet, floods: soaking through to outer clothing, floods: running down
12 +P | Hesitancy | Never, occasionally, sometimes, most of the time, all of the time
13 +P | Strain to start | Never, occasionally, sometimes, most of the time, all of the time
14 +P | Intermittency | Never, occasionally, sometimes, most of the time, all of the time
15 +P | Nocturnal incontinence | Never, occasionally, sometimes, most of the time, all of the time
16 +P | Reduced stream | Not reduced, reduced a little, quite reduced, reduced a great deal, no stream
17 | Acute retention | No, yes once, yes twice, yes more than twice
18 +P | Burning | Never, occasionally, sometimes, most of the time, all of the time
19 +P | Incomplete emptying | Never, occasionally, sometimes, most of the time, all of the time
20 | Stopping flow | Yes easily, yes with difficulty, no cannot stop the flowing
25 +P | Frequency (hours between voiding) | Every 4 hours or more, every 3 hours, every 2 hours, hourly
Sexual functioning
21 +P | Pain due to dry vagina | Not at all, a little, somewhat, a lot
22 +P | Sex life spoiled | Not at all, a little, somewhat, a lot
23 +P | Pain during intercourse | Not at all, a little, somewhat, a lot
24 +P | Leakage during intercourse | Not at all, a little, somewhat, a lot
Quality of life
10a | Change underclothes/wear protection | No, change underclothes, panty liners/mini pads, maxi/super sanitary towels, nappies/incontinence products
10b | Number of changes | No change, 1, 2–3, 4–5, more than 5 times
11 | Change outer clothing | Never, occasionally, sometimes, most of the time, all of the time
26 +P | Cut down fluid | Never, occasionally, sometimes, most of the time, all of the time
27 +P | Affect daily tasks | Never, occasionally, sometimes, most of the time, all of the time
28 +P | Avoidance of situations where no toilet | Never, occasionally, sometimes, most of the time, all of the time
29 +P | Interfere with physical activity | Never, occasionally, sometimes, most of the time, all of the time
30 +P | Interfere with social life | Never, occasionally, sometimes, most of the time, all of the time
31 | Overall interference with life | Never, occasionally, sometimes, most of the time, all of the time
32 | How long symptoms bothered | <1 year, 1–2 years, 2–3 years, more than 3 years
33 | Spend rest of life with no change | Perfectly happy, pleased, mostly satisfied, mixed feelings, mostly dissatisfied, very unhappy, desperate

+P indicates a linked question on the degree of the problem caused.

[underlined: Confidential BFLUTS-SF Questionnaire]
We would like to find out about your urinary symptoms and we are very grateful that you can help us by filling in this questionnaire. Please answer each question, thinking about the symptoms you have experienced in the last month.
You will see that some questions ask how often you have a symptom:
Occasionally = less than one third of the time
Sometimes = between one and two thirds of the time
Most of the time = more than two thirds of the time
Please put a tick in one box for each question ✓ □
F1 During the night, how many times do you have to get up to urinate, on average?
None - 0
1–1
2–2
3–3
4 or more - 4
F2 Do you have to rush to the toilet to urinate?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
F3 Do you have pain in your bladder?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
F4 How often do you pass urine during the day?
Every 4 hours or more - 0
Every 3 hours - 1
Every 2 hours - 2
Hourly - 3
BFLUTS-FS: sum scores F1–F4 - -
V1 Is there a delay before you can start to urinate?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
V2 Do you have to strain to urinate?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
V3 Do you stop and start more than once while you urinate?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
BFLUTS-VS: sum scores V1–V3 - -
I1 Does urine leak before you can get to the toilet?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
I2 How often do you leak urine?
Never - 0
Once or less per week - 1
2–3 times per week - 2
Once per day - 3
Several times per day - 4
I3 Does urine leak when you are physically active, exert yourself, cough, or sneeze?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
I4 Do you ever leak for no obvious reason and without feeling that you want to go?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
I5 Do you leak urine when you are asleep?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
BFLUTS-IS: sum scores 11–15 - -
S1 To what extent do you feel that your sex life has been spoiled by your urinary symptoms?
Not at all - 0
A little - 1
Somewhat - 2
A lot - 3
S2 Do you leak urine when you have sexual intercourse?
Not at all - 0
A little - 1
Somewhat - 2
A lot - 3
BFLUTS-sex: sum scores S1 & S2 - -
QoL1 Do you need to change your outer clothing during the day because of urine leakage?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
QoL2 Do you cut down on the amount of fluid you drink so that your urinary symptoms improve, and you can do the things that you want to do?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
QoL3 To what extent have your urinary symptoms affected your ability to perform daily tasks (eg, cleaning, DIY, lifting objects)?
Not at all - 0
A little - 1
Somewhat - 2
A lot - 3
QoL4 Do you avoid places and situations where you know a toilet is not nearby (eg, shopping, traveling, theater, church)?
Never - 0
Occasionally - 1
Sometimes - 2
Most of the time - 3
All of the time - 4
QoL5 Overall, how much do your urinary symptoms interfere with your life?
Not at all - 0
A little - 1
Somewhat - 2
A lot - 3
BFLUTS-QoL: Sum scores QoL1–QoL5 - -
[underlined: Stress and Urge Incontinence and Quality of Life Questionnaire (SUIQQ) ^858^]
The Stress Incontinence Index consists of 9 questions on activities that cause leakage (when the woman coughs, sneezes, laughs, walks up or down stairs, rises from the bed, lifts heavy objects and during physical activity, sports and intercourse).
- Frequency of stress incontinence episodes: never, 1–4 times a month, 1–6 times a week, once a day, and more than once daily)
- Amount of leakage: nothing, drops/moist underwear, dripping/wet underwear, running/passes through all clothes, and running down the legs or down to the floor).
The Urge Incontinence Index consists of two questions: how often and to what extent urge incontinence is experienced.
The Quality of Life Index: (1) the number of incontinence diapers used (none, 1–3 per week, 4–6 per week, 1–4 per day, and more than 4 per day), (2) how often activities are avoided due to fear of leakage (never, seldom, sometimes, often, always), (3) how often places or situations are avoided due to fear of leakage (never, seldom, sometimes, often, always), and (4) how leakage influences holidays, family life, social life and sleep during the night. These last four questions are marked ‘yes’, ‘no’ or ‘not relevant’. Except for the first stress incontinence item, therefore, all items are expressed in a scale of five categories, with scores of 0–4. The nine questions from the first stress item have possible choices ‘yes’, ‘no’ and ‘not relevant’. The sum score from the nine stress incontinence questions are recalculated into five categories (0, 1–3, 4–5, 6–7 and 8–9) to give this item the same relative weight as the others.
[underlined: The International Continence Society male questionnaire, short form ^859^]
We would like to find out about your urinary symptoms and we are very grateful that you can help us by filling in this questionnaire. Please answer each question, thinking about the symptoms you have experienced in the last month.
You will see that some questions ask how often you have a symptom:
Occasionally - less than one-third of the time
Sometimes - between one and two-thirds of the time
Most of the time - more than two-thirds of the time
Is there a delay before you can start to urinate?
Do you have to strain to continue urinating?
Would you say that the strength of your urinary stream is. . .
normal
occasionally reduced
sometimes reduced
reduced most of the time
reduced all of the time
Do you stop and start more than once while you urinate?
How often do you feel that your bladder has not emptied properly after you have urinated?
ICS male VS: sum scores V1–V5
Do you have to rush to the toilet to urinate?
Does urine leak before you can get to the toilet?
Does urine leak when you cough or sneeze?
Do you ever leak for no obvious reason and without feeling that you want to go?
Do you leak urine when you are asleep?
How often have you had a slight wetting of your pants a few minutes after you had finished urinating and had dressed yourself?
ICS male IS: sum scores I1–I6
Frequency
How often do you pass urine during the day?
hourly
every 2 hours
every 3 hours
every 4 hours or more
Nocturia During the night, how many times do you have to get up to urinate, on average?
none
one
two
three
four or more
QoL Overall, how much do your urinary symptoms interfere with your life?
not at all
a little
somewhat
a lot

[underlined: The International Continence Society male questionnaire, short form] ^859^
1 1P | Frequency (times daily) | 1–6, 7–8, 9–10, 11–12 1 131
2 1P | Nocturia | 0, 1, 2, 3 1 41
3 1P | Urgency | Never, occasionally, sometimes, most of time, all of time
4 1P | Urge incontinence | Never, occasionally, sometimes, most of time, all of time
5 1P | Bladder pain | Never, occasionally, sometimes, most of time, all of time
6 1P | Stress incontinence | Never, occasionally, sometimes, most of time, all of time
7 1P | Unpredictable miscellaneous incontinence | Never, occasionally, sometimes, most of time, all of time
8 1P | Hesitancy | Never, occasionally, sometimes, most of time, all of time
9 1P | Starting strain | Never, occasionally, sometimes, most of time, all of time
10 1P | Continuing strain | Never, occasionally, sometimes, most of time, all of time
11 1P | Urination seated | Standing, seated
12 1P | Decreased stream (words) | Normal, decreased, never, occasionally, sometimes, most of time, all of time
13 | Weak stream always | Yes, no
14 | Decreased stream (picture) | 4 Distances
15 1P | Intermittency | Never, occasionally, sometimes, most of time, all of time
16 1P | Dysuria | Never, occasionally, sometimes, most of time, all of time
17 1P | Incomplete emptying | Never, occasionally, sometimes, most of time, all of time
18 1P | Terminal dribbling | Never, occasionally, sometimes, most of time, all of time
19 1P | Post-void dribbling | Never, occasionally, sometimes, most of time, all of time
20 1P | Nocturnal incontinence | Never, occasionally, sometimes, most of time, all of time
22 1P | Repeat urination | Never, occasionally, sometimes, most of time, all of time
23 | Acute retention | No, 1, 2, more than 2
28 1P | Frequency (hrs. between voidings) | 4, 3, 2 hours., hourly

Possible responses for the following questions:
Occasionally - less than one third of the time
Sometimes - between one and two thirds of the time
Most of the time - more than two thirds of the time
-Is there a delay before you can start to urinate?
-Do you have to strain to continue urinating?
-Would you say that the strength of your urinary stream is
normal
occasionally reduced
sometimes reduced
reduced most of the time
reduced all of the time.
-Do you stop and start more than once while you urinate?
-How often do you feel that your bladder has not emptied properly after you have urinated?
-Do you have to rush to the toilet to urinate?
-Does urine leak before you can get to the toilet?
-Does urine leak when you cough or sneeze?
-Do you ever leak for no obvious reason and without feeling that you want to go?
-Do you leak urine when you are asleep?
-How often have you had a slight wetting of your pants a few minutes after you had finished urinating and had dressed yourself?
Frequency
-How often do you pass urine during the day?
hourly
every 2 hours
every 3 hours
every 4 hours or more
-During the night, how many times do you have to get up to urinate, on average?
none
one
two
three
four or more
-Overall, how much do your urinary symptoms interfere with your life?
not at all
a little
somewhat
a lot
[underlined: Overactive bladder symptom and health-related quality of life questionnaire] ^860^
This questionnaire asks about how much you have been bothered by selected bladder symptoms during the past 4 weeks. Please circle the number that best describes the extent to which you were bothered by each symptom during the past 4 weeks. There are no right or wrong answers. Please be sure to answer every question using possible responses: not at all, a little bit, somewhat, quite a bit, a great deal, a very great deal
During the past 4 weeks, how bothered were you by:
1 Frequent urination during the daytime hours; 2 An uncomfortable urge to urinate; 3 A sudden urge to urinate with little or no warning; 4 Accidental loss of small amounts of urine; 5 Nighttime urination; 6 Waking up at night because you had to urinate; 7 An uncontrollable urge to urinate; 8 Urine loss associated with a strong desire to urinate
During the past 4 weeks, how often have your bladder symptoms: none of the time, a little of the time, some of the time, a good bit of the time, most of the time, all of the time
9 Made you carefully plan your commute?; 10 Caused you to feel drowsy or sleepy during the day?; 11 Caused you to plan ‘escape routes’ to restrooms in public places?; 12 Caused you distress?; 13 Frustrated you?; 14 Made you feel like there is something wrong with you?; 15 Interfered with your ability to get a good night's rest?; 16 Caused you to decrease your physical activities (exercising, sports, etc.)?; 17 Prevented you from feeling rested upon waking in the morning?; 18 Frustrated your family and friends?; 19 Caused you anxiety or worry?; 20 Caused you to stay home more often than you would prefer?; 21 Caused you to adjust your travel plans so that you are always near a restroom?; 22 Made you avoid activities away from restrooms (i.e., walks, running, hiking)?; 23 Made you frustrated or annoyed about the amount of time you spend in the restroom?; 24 Awakened you during sleep?; 25 Made you worry about odor or hygiene?; 26 Made you uncomfortable while traveling with others because of needing to stop for a restroom?; 27 Affected your relationships with family and friends?; 28 Caused you to decrease participating in social gatherings, such as parties or visits with family or friends?; 29 Caused you embarrassment?; 30 Interfered with getting the amount of sleep you needed?; 31 Caused you to have problems with your partner or spouse?; 32 Caused you to plan activities more carefully?; 33 Caused you to locate the closest restroom as soon as you arrive at a place you have never been?
[underlined: Urogenital Distress Inventory] ^861^
Please indicate which symptoms you are now experiencing, and how bothersome they are for you. Be sure to answer all items.
Do you experience frequent urination? If yes, how much does it bother you? not at all; slightly; moderately; greatly
Do you experience a strong feeling of urgency to empty your bladder?
Do you experience urine leakage related to the feeling of urgency?
Do you experience urine leakage related to physical activity, coughing or sneezing?
Do you experience general urine leakage not related to urgency or activity?
Do you experience small amounts of urine leakage (that is, drops)?
Do you experience large amounts of urine leakage?
Do you experience nighttime urination?
Do you experience bedwetting?
Do you experience difficulty emptying your bladder?
Do you experience a feeling of incomplete bladder emptying?
Do you experience lower abdominal pressure?
Do you experience pain when urinating?
Do you experience pain in the lower abdominal or genital area?
Do you experience heaviness or dullness in the pelvic area?
Do you experience a feeling of bulging or protrusion in the vaginal area?
Do you experience bulging or protrusion you can see in the vaginal area?
Do you experience pelvic discomfort when standing or physically exerting yourself?
Do you have to push on the vaginal walls to have a bowel movement?
Other symptoms
[underlined: Incontinence impact questionnaire]
Some women find that accidental urine loss and/or prolapse may affect their activities, relationships, and feelings.
The questions below refer to areas in your life which may have been influenced or changed by your problem. For each question, check the response that best describes how much your activities, relationships, and feelings are being affected by urine leakage and/or prolapse. Responses: not at all; slightly; moderately; greatly
Has urine leakage and/or prolapse affected your:
Ability to do household chores (cooking, housecleaning, laundry)
Ability to do usual maintenance or repair work done in home or yard
Shopping activities
Hobbies and pastime activities
Physical recreational activities such as walking, swimming, or other exercise
Entertainment activities such as going to a movie or concert
Ability to travel by car or bus for distances less than 20 minutes away from home
Ability to travel by car or bus for distances greater than 20 minutes away from home
Going to places if you are not sure about available restrooms
Going on vacation
Church or temple attendance
Volunteer activities
Employment (work) outside the home
Having friends visit you in your home
Participating in social activities outside your home
Relationship with friends
Relationship with family excluding husband/companion
Ability to have sexual relations
Way you dress
Emotional health
Physical health
Sleep
Does fear of odor restrict your activities?
Does fear of embarrassment restrict your activities?
In addition, does your problem cause you to experience any of the following feelings?
Nervousness or anxiety
Fear
Frustration
Anger
Depression
Embarrassment
[underlined: Incontinence Severity Index] ^863^
How often do you experience urinary leakage?
Less than once a month
One or several times a month
Every day and/or night
How much urine do you lose each time?
Drops
Small splashes
More
The severity index is created by multiplying the results of questions 1 and 2:
1–2 = slight
3–4 = moderate
6–8- = severe
In the three-level severity index, responses to the second question are first aggregated into drops (1) and more (2), and then multiplied with the frequency, resulting in the following index values (1–8):
1–2 = slight
3–4 = moderate
6–8 = severe
The four-level severity index is based on the following index values (1–12):
1–2 = slight
3–6 = moderate
8–9 = severe
12 = very severe
[underlined: International Continence Society male, lower urinary tract symptoms primarily ^865^]
During the day, how many times do you urinate, on average?
1 to 6 times
7 to 8 times
9 to 10 times
11 to 12 times
13 or more times
How much of a problem is this for you?
Not a problem
A bit of a problem
Quite a problem
A serious problem
During the night, how many times do you have to get up to urinate, on average?
None
One
Two
Three
Four or more
How much of a problem is this for you?
Would you say that the strength of your urinary stream is
Normal
Occasionally reduced
Sometimes reduced
Reduced most of the time
Reduced all of the time
How much of a problem is this for you?
Please ring the number that corresponds with the strength of your urinary stream over the past month.
How often do you pass urine during the day?
Hourly
Every 2 hours
Every 3 hours
Every 4 hours or more
How much of a problem is this for you?
[underlined: Incontinence Quality of Life (in persons with UI) questionnaire ^867^]
I worry about not being able to get to the toilet on time.
I worry about coughing and sneezing.
I have to be careful about standing up after sitting down.
I worry where the toilets are in new places.
I feel depressed.
I don't feel free to leave my home for long periods of time.
I feel frustrated because my UI prevents me from doing what I want.
I worry about others smelling urine on me.
Incontinence is always on my mind.
It's important for me to make frequent trips to the toilet.
Because of my incontinence, it is important to plan every detail in advance.
I worry about my incontinence getting worse as I grow older.
I have a hard time getting a good night's sleep.
I worry about being embarrassed or humiliated be cause of my incontinence.
My incontinence makes me feel like I'm not a healthy person.
My UI makes me feel helpless.
I get less enjoyment out of life because of my UI.
I worry about wetting myself.
I feel like I have no control over my bladder.
I have to watch what I drink.
My UI limits my choice of clothing.
I worry about having sex.
All items use the following response scale:
1 = Extremely
2 = Quite a bit
3 = Moderately
4 = A little
5 = Not at all
Subscale structure:
Avoidance and limiting behavior: items 1, 2, 3, 4, 10, 11, 13, and 20
Psychosocial impacts: items 5, 6, 7, 9, 15, 16, 17, 21, and 22
Social embarrassment: items 8, 12, 14, 18, and 19

[underlined: Incontinence Classification System] ^868^
Domain | Nature of the Questions
Social interactions | Relationships with friends
| Relationships with spouse/companions
| Difficulty establishing new relationships
Personal strain | Interference with the ability to perform usual daily tasks
| Ability to engage in physical recreation
| Ability to engage in non strenuous recreation
| Nervousness or anxiety related to incontinence
Global health and quality of life | Effect on overall health
| Effect on overall level of energy
| Feelings of being less useful
| Overall quality of life
| Impact on quality of life if there was no incontinence
Satisfaction | Overall satisfaction with life
Financial | Effect on financial situation
Sexuality | Interference with sexual activity

[underlined: King's Health Questionnaire ^869^]
How would you describe your health at present? very good; good; fair; poor; very poor
How much do you think your bladder problem affects your life? not at all; a little; moderately; a lot
What are your bladder problems and how much do they affect you?
Frequency: (going to the toilet very often)
Nocturia: (getting up at night to pass urine)
Urgency: (a strong and difficult to control desire to pass urine)
Urge Incontinence: (urinary leakage associated with a strong desire to pass urine)
Stress Incontinence: (urinary leakage with physical activity e.g. coughing, sneezing or running)
Nocturnal Enuresis: (wetting the bed at night)
Intercourse Incontinence: (urinary leakage with sexual intercourse)
Frequent waterworks infections
Bladder pain
Difficulty passing urine
Below are some daily activities that can be affected by bladder problems. How much does your bladder problem affect you?
a To what extent does your bladder problem affect your household tasks (e.g. cleaning, shopping); b Does your bladder problem affect your job or your normal activities outside the home
Physical Limitations (Tick the box that applies to you)
a Does your bladder problem affect your physical activities (e.g. going for a walk, run, sport, gym etc.)?; b Does your bladder problem limit your ability to travel?
Social Limitations
a Does your bladder problem affect your social life?; b Does your bladder problem affect your ability to see/visit friends?
Personal Relationships
a Does your bladder problem affect your relationship with your partner?; b Does your bladder problem affect your sex life?; c Does your bladder problem affect your family life?
Emotions
a Does your bladder problem make you feel depressed?; b Does your bladder problem make you feel anxious or nervous?; c Does your bladder problem make you feel bad about yourself?
Sleep/Energy
a Does your bladder problem affect your sleep?; b Do you feel worn out/tired?
Do you do any of the following? If so how much?
a Wear pads to keep dry?; b Be careful how much fluid you drink?; c Change you underclothes when they get wet?; d Worry in case you smell?; e Get embarrassed because of your bladder problem?
[underlined: Incontinence Impact Questionnaire-7 ^862^]
Some people find that accidental urine loss may affect their activities, relationships, and feelings. The questions below refer to areas in your life that may have been influenced or changed by your problem. For each question, circle the response that best describes how much your activities, relationships, and feelings are being affected by urine leakage.
Has urine leakage affected your: not at all=1; slightly=1; moderately=2; greatly=3
Ability to do household chores (cooking, housecleaning, laundry)?
Physical recreation such as walking, swimming, or other exercise?
Entertainment activities (movies, concerts, etc.)?
Ability to travel by car or bus more than 30 minutes from home?
Participation in social activities outside your home?
Emotional health (nervousness, depression, etc.)?
Feeling frustrated?
Items 1 and 2 = physical activity
Items 3 and 4 = travel
Item 5 = social/relationships
Items 6 and 7 = emotional health
Scoring. Item responses are assigned values of 0 for “not at all,” 1 for “slightly,” 2 for “moderately,” and 3 for “greatly.” The average score of items responded to is calculated. The average, which ranges from 0 to 3, is multiplied by 33 1/3 to put scores on a scale of 0 to 100.
[underlined: UI Severity Score (UISS)] ^871^ ^872^
The UISS questionnaire consists of 10 questions designed to quantify the amount of leakage, the degree to which UI affects aspects of a woman's daily life, and need to use pads. The responses are scored from 0 to 2, yielding a total score between 0 and 20. The lower scores reflect better quality of life. Marking the most appropriate alternative: not at all=0; sometimes=1; often=2.
1 Do you experience urine leakage not related to effort or position (for example lying down)?; 2 Do you experience urine leakage related to minor physical activity (e.g. walking or rising)?; 3 Do you experience urine leakage related to sudden, strong physical activity or even coughing or sneezing?; 4 Has urine leakage disturbed your daily chores (shopping, cooking, housecleaning etc.)?; 5 Has urine leakage disturbed your employment (client service, work performance etc)?; 6 Are you afraid that others will notice your problem (fear of your odour or wetness etc.)?; 7 Do you have to restrict or give up social activities (such as visiting friends, physical activity, theatre, church etc.)?; 8 Do your incontinence symptoms disturb your sex life?; 9 Does incontinence cause irritation of your external genital organs?; 10 How often must you use a protective nappy or pad?
[underlined: CONTILIFE- Urinary Incontinence-Specific Measure of Quality of Life] ^873^
The following questions are about your health over the last 4 weeks. Choose the answer which best describes what you feel or have felt over the last 4 weeks giving only one answer per line. If certain activities do not apply (e.g. embarrassment when using public transport because you do not use public transport), put a tick in the “not applicable” box. Please answer this questionnaire on your own, without help. To answer, tick the box which applies to you: not at all; a little; moderately; a lot; extremely
DAILY ACTIVITIES
Over the last 4 weeks, how much have your urinary problems bothered you:
1 When you were away from your home?; 2 When you were driving or being a passenger?; 3 When going up or down stairs?; 4 When shopping?; 5 When queuing (bus stop, cinema, supermarket)?
Over the last 4 weeks, because of your urinary problems: none; a few; some; many; very many
6 Have you had to take frequent breaks during your work or daily activities?
Over the last 4 weeks, because of your urinary problems, how often: never; rarely; sometimes; often; all the time
7 Have you woken up having wet yourself?
EFFORT
Over the last 4 weeks, how much have your urinary problems bothered you: not at all; a little; moderately; a lot; extremely
8 When lifting or carrying heavy objects?; 9 When doing sport (running, dancing, keep-fit)?; 10 When blowing your nose, sneezing or coughing?; 11 After a fit of laughter?
SELF IMAGE
Over the last 4 weeks, because of your urinary problems, how often: never; rarely; sometimes; often; all the time
12 Have you felt less attractive?; 13 Were you afraid of giving off unwanted odors?; 14 Were you afraid that other people might become aware of your problems?; 15 Were you afraid of leaving stains at other people's homes or at work?; 16 Did you have to change your clothes?
Over the last 4 weeks, in spite of your urinary problems, how often: never; rarely; sometimes; often; all the time
17 Have you felt at ease with yourself?
Over the last 4 weeks, because of your urinary problems: I never wear pads; not at all; a little; moderately; a lot; extremely
18 Have you been bothered by having to wear pads?
EMOTIONAL CONSEQUENCES
Over the last 4 weeks, because of your urinary problems, how often: never; rarely; sometimes; often; all the time
19 Have you felt discouraged?; 20 Have you lost patience?; 21 Have you been worried that you might have a urinary “accident”?; 22 Have you felt that you are losing self-control?; 23 Have you felt obsessed by your urinary problems?; 24 Did you need to think about taking pads with you before going out?
SEXUALITY
Over the last 4 weeks, because of your urinary problems, how much: not at all; a little; moderately; a lot; extremely
25 Have you felt anxious at the thought of having sexual intercourse?; 26 Have you changed your sexual practices?; 27 Have you been afraid of having urine leaks during sexual intercourse?
OVERALL QUALITY OF LIFE
28 Taking your urinary problems into account, how would you currently assess your quality of life? From Poor to Excellent (5 scores)

Table F212 Association between sample size of studies and diagnostic values of tests

Questionnaires and Scales | Intercept | Slope | R2, %
Sensitivity, % | 75.1 | 0.01 | 2.4
Specificity, % | 68.9 | 0.02 | 1.1
Positive predictive likelihood | 12.4 | -0.02 | 4.1
Clinical history for stress UI
Sensitivity | 93.6 | -0.02 | 19.5
Specificity | 57.8 | 0.00 | 0.3
Positive predictive likelihood | 70.9 | 0.03 | 21.7
Positive likelihood ratio | 4.0 | 0.00 | 4.9
Clinical history for urge UI
Sensitivity, % | 55.3 | -0.01 | 7.2
Specificity | 77.3 | 0.00 | 0.1
PPV+ | 66.5 | 0.00 | 0.1
LR+ | 7.0 | 0.00 | 1.7
Ultrasound
Sensitivity, % | 85.9 | -0.05 | 10.2
Specificity, % | 89.6 | -0.04 | 8.2
Positive predictive likelihood | 1.0 | 0.00 | 52.2
Positive likelihood ratio | 7.8 | 0.03 | 2.3

Table F213 Scales that provided the largest positive likelihood ratio to detect UI

Author, positive likelihood ratio | Questions
Sandvik, 1995 ^841^ | A positive answer to the following question was presumed to be an indication of stress incontinence:
LR+ 14 | “Do you lose urine during sudden physical exertion, lifting, coughing or sneezing?” Urge incontinence was presumed to be indicated by a positive answer to the question:
| “Do you experience such a strong and sudden urge to void that you leak before reaching the toilet?”
| A positive answer to both questions was registered as mixed incontinence.
Kirschner-Hermanns, 1998 ^874^ | How long can you usually hold urine once you feel an urge to urinate?
LR+ 15 | More than 5 minutes
| 1 to 5 minutes
| Less than 1 minute, or I have an urge but I can't hold it
| I have no urge or warning
| Do you ever lose urine when you laugh, cough, sneeze or bend over?
| Is the only time that you lose urine when you laugh, cough, sneeze or bend over?
| When you are awake, can you usually go for half an hour without leaking urine?
| When you lose urine, how much usually leaks?
| A few drops
| Enough to wet your underwear
| Enough to wet your outer clothes, or enough to wet the floor
Diokno, 1999 ^875^ | The Medical, Epidemiologic and Social Aspects of Aging Urinary Incontinence Questionnaire
LR+ 62 | Please check the appropriate box
| 1. Over the past 12 months, have you had urine loss beyond your control?
| [ ] Yes [ ] No
| 2. How long ago did your urine loss start? years, months, days
| 3. When does the urine loss usually occur:
| [ ] Daytime only
| [ ] Nighttime only
| [ ] Both daytime and nighttime
| Questions for Urge Incontinence symptoms:
| Please check the appropriate box: [ ] Often (3); [ ] Sometimes (2); [ ] Rarely (1); [ ] Never (0)
| 1. Some people receive very little warning and suddenly find that they are losing, or about to lose, urine beyond their control. How often does this happen to you?
| 2. If you can't find a toilet or find that the toilet is occupied, and you have an urge to urinate, how often do you end up losing urine and wetting yourself?
| PREDICTING TYPE II STRESS INCONTINENCE
| Please check the appropriate box: [ ] Often (3); [ ] Sometimes (2); [ ] Rarely (1); [ ] Never (0)
| 3. Do you lose urine when you suddenly have the feeling that your bladder is very full?
| 4. Does washing your hands cause you to lose urine?
| 5. Does cold weather cause you to lose urine?
| 6. Does drinking cold beverages cause you to lose urine?
| Total urge score:
| Urge score ratio:
| Questions for Stress Incontinence symptoms:
| 1 Does coughing gently cause you to lose urine?; 2 Does coughing hard cause you to lose urine?; 3 Does sneezing cause you to lose urine?; 4 Does lifting things cause you to lose urine?; 5 Does bending over cause you to lose urine?; 6 Does laughing cause you to lose urine?; 7 Does walking briskly or jogging cause you to lose urine?; 8 Does straining, if you are constipated, cause you to lose urine?; 9 Does getting up from a sitting to standing position cause you to lose urine?
| Total stress score:
| Stress score ratio:
Moore, 1996 ^876^ | Screening Measure (2 parts)
LR+ 17.8 | Ask: "In the last year, have you ever lost your urine gotten wet?
| If yes, then ask: "Have you lost urine on at least 6 separate days?

Table F214 Diagnostic value of different tests to detect persons at risk and patients with UI

Author | UI Type | Index Method vs. “Gold Standard” | Sensitivity (%) | Specificity (%) | Positive Predictive Likelihood
Sample
Richardson, 1986 ^877^ | Stress | Urethral pressure profile vs. urodynamics | 86 | 58 | 2.05
N = 144 | | Urethral pressure profile vs. multichannel UD, supine | 32 | 93 | 4.57
| | Urethral pressure profile vs. multichannel UD, standing | 41 | 92 | 5.13
Schick, 2004 ^878^ | Stress | Urethral pressure profile vs. urodynamics | 53.8 | 75.9 | 2.23
N = 369
Romanzi, 1999 ^879^ | Pelvic muscle strength | Pelvic scale scores vs. clinical history | 68 | 71 | 2.34
N = 57
Fischer-Rasmusen, 1986 ^880^ | Stress | Pelvic scale scores vs. clinical history | 72 | 46 | 1.33
N = 212 | | Cystoscopy, cystometry, stress test for urine loss, uroflowmetry, and colpo-cysto-urethrography vs. clinical history | 52 | 85 | 3.47
Resnick, 1996 ^881^ | Urge | Minimum data sgorithm vs. urodynamics | 76 | 71 | 2.62
N = 102 | Stress | Minimum data sgorithm vs. urodynamics | 76 | 97 | 25.33
Summit, 1992 ^882^ | Stress | Cough stress test and single-channel medium-fill cystometry vs. urodynamics | 94 | 84 | 5.88
N = 90 | Urge | | 71 | 96 | 17.75
| Mixed | | 94 | 84 | 5.88
Creighton, 1991 ^883^ | Mixed | Urethral electrical conductance vs. urodynamics | 64 | 86 | 4.57
N = 133
Davis, 1998 ^884^ | Stress | Ambulatory urodynamic monitoring vs. multichannel UD | 78 | 7 | 0.84
N = 60
Rosario, 1999 ^885^ | Bladder outlet obstruction | Ambulatory urodynamic monitoring vs. multichannel UD | 25 | 88 | 2.08
N = 63
Mclnerney, 1991 ^886^ | Urge | Ambulatory urodynamic monitoring vs. multichannel UD | 100 | 58 | 2.38
N = 20
Bhatia, 1982 ^887^ | Urge | Ambulatory urodynamic monitoring vs. multichannel UD | 43 | 58 | 1.02
N = 26
Swift, 1995 ^888^ | Stress | Urethral pressure profile vs. multichannel UD | 49 | 98 | 24.50
N = 108
Versi, 1990 ^889^ | Stress | Urethral pressure profile vs. multichannel UD | 77 | 79 | 3.67
N = 172
Pajoncini, 1999 ^890^ | Stress | Urethral pressure profile vs. multichannel UD, VLPP | 84 | 60 | 2.10
N = 119 | Stress | Urethral pressure profile vs. multichannel UD, MUCP | 63 | 52 | 1.31
Versi, 1991 ^891^ | Stress | Urethral pressure profile vs. multichannel UD | 48 | 84 | 3.00
N = 303
Cucchi, 1990 ^892^ | Urge | Flow rate acceleration vs. multichannel UD | 75 | 75 | 3.00
N = 40
Swift, 1997 ^893^ | Urge | Cystometry by fetal monitor vs. multichannel UD | 91 | 86 | 6.50
N = 66
Bergman, 1988 ^894^ | Urge | Cystometry by fetal monitor vs. multichannel UD | 100 | 96 | 25.00
N = 35
Petersen, 1997 ^895^ | Urge | Ice water test vs. multichannel UD | 85 | 65 | 2.43
N = 130
Sutherst, 1981 ^896^ | Stress | Fluid bridge test to detect the entry of urine into the proximal urethra during cough vs. standing cystometry, supine | 86 | 42 | 1.48
N = 126 | Stress | Fluid bridge test to detect the entry of urine into the proximal urethra during cough vs. standing cystometry, standing | 100 | 24 | 1.32
Hanzal, 1991 ^897^ | Stress | Urethral pressure profile vs. clinical stress test | 93 | 83 | 5.47
N = 981
Frigerio, 1981 ^898^ | Urge | Voiding stop tests vs. single channel cystometry | 95 | 66 | 2.79
N = 112

Table F215 Diagnostic value of different tests compared to multichannel urodynamics to detect UI in adults

Author | Sensitivity (%) | Specificity (%) | Positive Predictive Likelihood
Sample
X-ray
Pelsang, 1996 ^899^ | 61 | 70 | 2.03
N = 159
100% female
Scotti, 1990 ^900^ | 60 | 79 | 2.86
N = 204
100% female
Grischke, 1991 ^901^ | 59 | 60 | 1.48
N = 84
100% female
Bergman. 1988 ^902^ | 100 | 44 | 1.79
N = 59
100% female
Rose, 1983 ^903^ | 91 | 91 | 10.11
N = 1,584
69% female
Digesu, 2004 ^904^ | 45 | 83 | 2.65
N = 4,500
100% female
Full bladder clinical test
Hsu, 1999 ^905^ | 94 | 90 | 9.40
N = 41
100% female
Kadar, 1988 ^906^ | 78 | 74 | 3.00
N = 37
100% female
Scotti, 1993 ^907^ | 84 | 84 | 5.25
N = 145
100% female
Resnik, 1996 ^908^ | 67 | 98 | 33.50
N = 97
100% female
Lobel, 1996 ^909^ | 49 | 95 | 9.80
N = 304
100% female
Single channel urodynamics for stress UI
Swift, 1997 ^893^ | 49 | 98 | 24.50
N = 66
100% female
Ouslander, 1988 ^910^ | 73 | 61 | 1.87
N =164
78% female
Resnick, 1996 ^908^ | 86 | 86 | 6.14
N = 97
100% female
Scotti, 1993 ^907^ | 49 | 95 | 9.80
N = 145
100% female
Single channel urodynamics for urge UI
Swift, 1997 ^893^ | 49 | 98 | 24.50
N = 66
100% female
Ouslander, 1988 ^910^ | 73 | 61 | 1.87
N =164
78% female
Resnick, 1996 ^908^ | 86 | 86 | 6.14
N = 97
100% female
Scotti, 1993 ^907^ | 49 | 95 | 9.80
N = 145
100% female
Q-tip test
Bergman, 1987 ^911^ | 75 | 58 | 1.79
N =105
100% female
Montz, 1986 ^912^ | 53 | 53 | 1.13
N = 100
100% female
Thomakos, 2005 ^913^ | 91 | 35 | 1.40
N = 539
100% female
Noblett, 2005 ^914^ | 94 | 91 | 10.44
N = 134 | 96 | 84 | 6.00
100% female

Table F216 Number needed to screen and number of tests to detect 1 case of UI in men ^915,^ ^916^

Prevalence of Undiagnosed UI | | Clinical History to Diagnose Detrusor Overactivity | | Scale to Diagnose Detrusor Overactivity
Population Categories | | Number Needed to Screen | Number of Tests | Number Needed to Screen | Number of Tests
All | 0.782 | 24 | 5 | 8 | 6
Race/ethnicity
Black | 0.73 | 20 | 4 | 9 | 7
Hispanic | 0.868 | 33 | 6 | 8 | 6
White | 0.788 | 26 | 5 | 8 | 6
Age group
30–39 | 0.962 | 16 | 4 | 7 | 5
40–49 | 0.822 | 29 | 5 | 8 | 6
50–59 | 0.904 | 31 | 6 | 7 | 6
60–79 | 0.621 | 27 | 5 | 11 | 8
Socioeconomic status
Low | 0.614 | 30 | 6 | 11 | 8
Middle | 0.782 | 24 | 5 | 8 | 6
High | 0.828 | 24 | 5 | 8 | 6
Medical insurance
Any private | 0.797 | 24 | 5 | 8 | 6
Public only | 0.717 | 26 | 5 | 9 | 7
None | 0.916 | 24 | 5 | 7 | 6

Table F217 Recommended questionnaires for symptoms and quality of life impact of anal incontinence (adapted from the Symptom and Quality of Life Committee of the International Consultation on Incontinence) ^855^

Grade | Questionnaire
Grade A (highly recommended): validity, reliability and responsiveness established with rigor | None
Grade B (recommended): validity and reliability established with rigor or validity, reliability and responsiveness indicated | Fecal Incontinence QOL Scale ^917^
| Manchester Health Questionnaire ^918^
| Birmingham Bowel and Urinary Symptoms Questionnaire ^919^

Table F218 Questionnaires with rigorous validity, reliability, and responsiveness highly recommended by the Symptom and Quality of Life Committee of the International Consultation on Incontinence for anal incontinence ^855^

[underlined: Fecal Incontinence QOL Scale ^917^]
In general, would you say your health is: excellent; very good; good; fair; poor
For each item, please indicate how much of the time the issue is a concern for you due to accidental bowel leakage. (If it is a concern for you for reasons other than accidental bowel leakage, then check the box under Not Apply, (N/A).) Most of the time; Some of the time; A little of the time; None of the time
Q1. Due to accidental bowel leakage
a I am afraid to go out; b I avoid visiting friends; c I avoid staying overnight away from home; d It is difficult for me to get out and do things like going to a movie or to church; e I cut down on how much I eat before I go out; f Whenever I am away from home, I try to stay near a restroom as much as possible; g It is important to plan my schedule (daily activities) around my bowel pattern; h I avoid traveling; i I worry about not being able to get to the toilet in time; j I feel I have no control over my bowels; k I can't hold my bowel movement long enough to get to the bathroom; l I leak stool without even knowing it; m I try to prevent bowel accidents by staying very near a bathroom
Q2: Due to accidental bowel leakage, indicate the extent to which you AGREE or DISAGREE with each of the following items. (If it is a concern for you for reasons other than accidental bowel leakage then check the box under Not Apply, N/A). Strongly agree; Somewhat agree; Somewhat disagree; Strongly disagree
Q3. Due to accidental bowel leakage:
a I feel ashamed; b I can not do many of things I want to do; c I worry about bowel accidents; d I feel depressed; e I worry about others smelling stool on me; f I feel like I am not a healthy person; g I enjoy life less; h I have sex less often than I would like to; i I feel different from other people; j The possibility of bowel accidents is always on my mind; k I am afraid to have sex; l I avoid traveling by plane or train; m I avoid going out to eat; n Whenever I go someplace new, I specifically locate where the bathrooms are
Q4: During the past month, have you felt so sad, discouraged, hopeless, or had so many problems that you wondered if anything was worthwhile? Extremely so - to the point that I have just about given up; Very much so; Quite a bit; Some - enough to bother me; A little bit; Not at all
[underlined: Manchester Health Questionnaire ^918^]
1. How do you describe you health at the present? Very good; Good; Fair; Poor; Very poor
2. How much you think your bowel problem affects your life? Not at all; A little bit; Moderately; Quite a bit; Extremely
We would like to know what your bowel problems are and how much they affect you.
Responses: Never; Occasionally; Sometimes; Most of the time; All of the time
3. How often do you have a strong desire to move your bowels which makes you rush to the toilet?
4. How often your bowels leak when coughing or sneezing?
5. How often your bowels leak when walking?
6. Do your bowels leak during the rest of the day or at night?
7. Do you have difficulties wiping clean after you have opened your bowels?
8. Do you have difficulties controlling wind?
9. Is the leakage from your bowels loose?
10. Is the leakage from your bowels solid?
11. How often do you move your bowels every day?
12. Do your bowels leak during or after sexual intercourse?
How much does the bowel problem you described in the previous page affect you?
Role limitation
13. Does your bowel problem affect you doing your jobs within the home?
14. Does your bowel problem affect your job or your normal daily activities outside the home?
Physical limitations
15. Does your bowel problem affect your ability to travel?
16. Does your bowel problem affect your physical activities (going for a walk, running, sport, gym, etc.?
17. Does your bowel problem limit your social life?
18. Does your bowel problem limit your ability to see and visit friends?
Personal relationships
19. Does you bowel problem affect your relationship with your partner?
20. Does you bowel problem affect your sex life?
21. Does you bowel problem affect your family life?
Emotions
22. Does you bowel problem make you feel depressed?
23. Does you bowel problem make you feel anxious or nervous?
24. Does your bowel problem make you feel bad about yourself?
Sleep/energy
25. Does your bowel problem affect your sleep?
26. Does your bowel problem make you feel worn out and tired?
Do you do any of following? If so how much?
27. Wear pads to keep clean?
28. Be careful how much food you eat?
29. Change your underclothes because they get dirty?
30. Worry in case you smell?
31. Get embarrassed because of you bowel problem?
[underlined: Modified Manchester Health Questionnaire]
SECTION A Responses: Never, Occasionally, Sometimes, Most of the time, All of the time
A1. How often do you have a strong desire to move your bowels that makes you rush to the toilet?
A2. How often in the past month have you experienced any amount of accidental bowel leakage that consisted of solid stool?
B1. Do you lose any solid stool when coughing or sneezing?
B2. Do you lose any solid stool when walking?
B3. Besides coughing, sneezing, and walking, do you lose any solid stool during the rest of the day or night?
A3. How often in the past month have you experienced any amount of accidental bowel leakage that consisted of liquid stool?
B4. When you leak stool, how often is it liquid or watery?
B5. Do you lose any liquid stool when coughing or sneezing?
B6. Do you lose any liquid stool when walking?
B7. Besides coughing, sneezing, and walking, do you lose any liquid stool during the rest of the day or night?
A4. How often in the past month have you experienced any amount of accidental bowel leakage that consisted of mucus?
A5. How often in the past month have you experienced any amount of accidental bowel leakage that consisted of gas?
B8. Do you lose any gas when coughing or sneezing?
B9. Do you lose any gas when walking?
SECTION C: If the answers to A1, A2, A3, A4, and A5 are all “Never,” skip this section.
C1. How much do you think your bowel problem affects your life?
C2. How often do you move your bowels each day?
C3. Do you have difficulty wiping clean after you have moved your bowels?
C4. What percent of your bowel movements are hard or little balls?
C5. What percent of your bowel movements are loose or watery?
Role limitations
C6. Do you have a problem with your bowels that affects doing jobs within the home?
C6a. If so, how often does it affect you?
C7. Do you have a problem with your bowels that affects your job, or your normal daily activities outside the home?
C7a. If so, how often does it affect you?
Physical/social limitations
C8. Do you have a problem with your bowels that affects your ability to travel?
C8a. If so, how often does it affect you?
C9. Do you have a problem with your bowels that affects your physical activities (such as going for a walk, running, sport, gym, etc.)?
C9a. If so, how often does it affect you?
C10. Do you have a problem with your bowels that limits your social life?
C10a. If so, how often, does it affect you?
C11. Do you have a problem with your bowels that limits your ability to see and visit friends?
C11a. If so, how often does it affect you?
Personal relationships
C12. Do you have a problem with your bowels that affects your relationship with your partner?
C12a. If yes, how often does it affect your relationship?
C13. Do you have a problem with your bowels that affects your family life?
C13a. If so, how often does it affect your family life?
Emotions
C14. Do you have a problem with your bowels that makes you feel depressed?
C14a. If yes, how often does it affect you?
C15. Do you have a problem with your bowels that makes you feel anxious or nervous?
C15a. If yes, how often does it affect you?
C16. Do you have a problem with your bowels that makes you feel bad about yourself?
C16a. If yes, how often does it affect you?
Sleep/energy
C17. Do you have a problem with your bowels that affects your sleep?
C17a. If so, how often does it affect your sleep?
C18. Do you have a problem with your bowels that makes you feel worn out and tired?
C18a. If yes, how often does it affect you?
Sexual Activity
For general audience, skip questions C19a to C19b.
C19. Have you resumed sexual activity since delivery?
C19a. If “Yes,” when did you resume sexual activity? _ _ weeks after delivery
C19b. If “No,” why have you not resumed sexual activity?
C20. Do you have a problem with your bowels that affects your sex life?
C20a. If so, how often does it affect your sex life?
C21. Do you lose any gas during or after sexual activity?
C22. Do you lose any stool during or after sexual activity?
C23. Do you lose any urine during or after sexual activity?
Lifestyle Adaptation
C24. Do you wear pads to keep clean because of a problem with your bowels?
C24a. If yes, how often do you wear pads?
C25. Are you careful about how much food you eat because of a problem with your bowels?
C25a. If yes, how often are you careful about how much food you eat?
C26. Do you change your underclothes because they get dirty due to a problem with your bowels?
C26a. If yes, how often do you change your underclothes for this reason?
C27. Do you worry about odor because of a problem with your bowels?
C27a. If yes, how often do you worry about it?
C28. Do you get embarrassed because of a problem with your bowels?
C28a. If yes, how often do you get embarrassed?
Medical
C29. Did you bring any of your bowel symptoms to the attention of your clinician?
C30. Have you received treatment for your bowel symptoms?
C30a. If “Yes,” please specify:
[underlined: Birmingham Bowel and Urinary Symptoms Questionnaire ^919^]
1 How often do you open your bowels?; 2 What form are your motions usually?; 3 Can you hold onto your motions for more than five minutes?; 4 Do you ever have to rush to the toilet to open your bowels?; 5 Does stool leak before you can get to the toilet?; 6 Do you leak stool for no obvious reason and without feeling that you want to go to the toilet?; 7 Do you have to strain to open your bowels?; 8 How long do you spend on the toilet, on average, for each bowel action?; 9 Do you feel that you cannot completely empty your bowels?; 10 Do you use a finger or pressure to help open your bowels?; 11 Do you use a finger in your vagina to help open your bowels?; 12 Do you have the urge to open your bowels but are unable to pass a motion?; 13 Do you find it painful to have your bowels open?; 15 Do you use laxatives?; 16 During the day, how many times do you urinate, on average?; 17 During the night, how many times do you have to get up to urinate, on average?; 18 Do you have to rush to the toilet to urinate?; 19 Do you have difficulty completely emptying your bladder?; 20 Does urine leak before you can get to the toilet?; 21 Does urine leak when you are active, exert yourself, cough, or sneeze?; 22 Does urine leak for no obvious reason and without feeling that you want to go to the toilet?

Figure F1. Prevalent UI in Asian women compared to Caucasian women

Figure F2. Association between sample size and sensitivity (%) of clinical history versus multichannel urodynamics to detect stress UI

Figure F3. Association between sample size and positive predictive value (%) of clinical history versus multichannel urodynamics to detect stress UI

## References for Appendix F

(Note that there is a separate set of references for the appendixes than for the report; therefore reference numbers are different)

1 Townsend MK, Danforth KN, Rosner B, et al. Body Mass Index, Weight Gain, and Incident Urinary Incontinence in Middle-Aged Women. Obstet Gynecol. Aug. 2007;110(2):346-53. [pmid: 17666610].
2 Altman D, Ekstrom A, Gustafsson C, et al. Risk of urinary incontinence after childbirth: a 10-year prospective cohort study. Obstet Gynecol. Oct. 2006;108(4):873-8. [pmid: 17012448].
3 Edwards DF, Hahn M, Dromerick A. Post stroke urinary loss, incontinence and life satisfaction: when does post-stroke urinary loss become incontinence?. Neurourol Urodyn. 2006;25(1):39-45. [pmid: 16299814].
4 Engh MA, Otterlind L, Stjerndahl JH, et al. Hysterectomy and incontinence: a study from the Swedish national register for gynecological surgery. Acta Obstet Gynecol Scand. 2006;85(5):614-8. [pmid: 16752243].
5 Glazener CM, Herbison GP, MacArthur C, et al. New postnatal urinary incontinence: obstetric and other risk factors in primiparae. Bjog. Feb. 2006;113(2):208-17. [pmid: 16412000].
6 McGrother CW, Donaldson MM, Hayward T, et al. Urinary storage symptoms and comorbidities: a prospective population cohort study in middle-aged and older women. Age Ageing. Jan. 2006;35(1):16-24. [pmid: 16234314].
7 van Brummen HJ, Bruinse HW, van de Pol G, et al. Bothersome lower urinary tract symptoms 1 year after first delivery: prevalence and the effect of childbirth. BJU Int. Jul. 2006;98(1):89-95. [pmid: 16831150].
8 van Brummen HJ, Bruinse HW, van der Bom JG, et al. How do the prevalences of urogenital symptoms change during pregnancy?. Neurourol Urodyn. 2006;25(2):135-9. [pmid: 16299813].
9 Wehrberger C, Temml C, Ponholzer A, et al. Incidence and remission of female urinary incontinence over 6.5 years: analysis of a health screening project. Eur Urol. Aug. 2006;50(2):327-32. [pmid: 16517050].
10 Andersson G, Johansson JE, Garpenholt O, et al. Urinary incontinence—prevalence, impact on daily living and desire for treatment: a population-based study. Scand J Urol Nephrol. 2004;38(2):125-30. [pmid: 15204395].
11 Bogner HR. Urinary incontinence and psychological distress in community-dwelling older African Americans and whites. J Am Geriatr Soc. Nov. 2004;52(11):1870-4. [pmid: 15507064].
12 Corcos J, Schick E. Prevalence of overactive bladder and incontinence in Canada. Can J Urol. Jun. 2004;11(3):2278-84. [pmid: 15287994].
13 Dallosso H, Matthews R, McGrother C, et al. Diet as a risk factor for the development of stress urinary incontinence: a longitudinal study in women. Eur J Clin Nutr. Jun. 2004;58(6):920-6. [pmid: 15164113].
14 Dallosso HM, McGrother CW, Matthews RJ, et al. The association of diet and other lifestyle factors with overactive bladder and stress incontinence: a longitudinal study in women. BJU Int. Jul. 2003;92(1):69-77. [pmid: 12823386].
15 Deliveliotis C, Liakouras C, Delis A, et al. Prostate operations: long-term effects on sexual and urinary function and quality of life. Comparison with an age-matched control population. Urol Res. Aug. 2004;32(4):283-9. [pmid: 15057494].
16 Grodstein F, Lifford K, Resnick NM, et al. Postmenopausal hormone therapy and risk of developing urinary incontinence. Obstet Gynecol. Feb. 2004;103(2):254-60. [pmid: 14754692].
17 Hagglund D, Walker-Engstrom ML, Larsson G, et al. Changes in urinary incontinence and quality of life after four years. A population-based study of women aged 22–50 years. Scand J Prim Health Care. Jun. 2004;22(2):112-7. [pmid: 15255492].
18 Haltbakk J, Hanestad BR, Hunskaar S. Diversity of urinary symptoms in patients tentatively diagnosed with benign prostatic hyperplasia referred to a urologic clinic in Norway. Scand J Urol Nephrol. 2004;38(6):454-61. [pmid: 15841777].
19 Holroyd-Leduc JM, Mehta KM, Covinsky KE. Urinary incontinence and its association with death, nursing home admission, and functional decline. J Am Geriatr Soc. May. 2004;52(5):712-8. [pmid: 15086650].
20 Hunskaar S, Lose G, Sykes D, et al. The prevalence of urinary incontinence in women in four European countries. BJU Int. Feb. 2004;93(3):324-30. [pmid: 14764130].
21 Jackson RA, Vittinghoff E, Kanaya AM, et al. Urinary incontinence in elderly women: findings from the Health, Aging, and Body Composition Study. Obstet Gynecol. Aug. 2004;104(2):301-7. [pmid: 15292003].
22 Jackson SL, Boyko EJ, Scholes D, et al. Predictors of urinary tract infection after menopause: a prospective study. Am J Med. Dec 15. 2004;117(12):903-11. [pmid: 15629728].
23 Johnson TK, Gilliland FD, Hoffman RM, et al. Racial/Ethnic differences in functional outcomes in the 5 years after diagnosis of localized prostate cancer. J Clin Oncol. Oct 15. 2004;22(20):4193-201. [pmid: 15483030].
24 Lagergren M, Fratiglioni L, Hallberg IR, et al. A longitudinal study integrating population, care and social services data. The Swedish National study on Aging and Care (SNAC). Aging Clin Exp Res. Apr. 2004;16(2):158-68. [pmid: 15195992].
25 Liebling RE, Swingler R, Patel RR, et al. Pelvic floor morbidity up to one year after difficult instrumental delivery and cesarean section in the second stage of labor: a cohort study. Am J Obstet Gynecol. Jul. 2004;191(1):4-10. [pmid: 15295337].
26 McGrother CW, Donaldson MM, Shaw C, et al. Storage symptoms of the bladder: prevalence, incidence and need for services in the UK. BJU Int. Apr. 2004;93(6):763-9. [pmid: 15049987].
27 Neumann G, Olesen PG, Hansen V, et al. The short-term prevalence of de novo urinary symptoms after different modes of hysterectomy. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):14-9. discussion 9. [pmid: 14752593].
28 Ostbye T, Seim A, Krause KM, et al. A 10-year follow-up of urinary and fecal incontinence among the oldest old in the community: the Canadian Study of Health and Aging. Can J Aging. Winter. 2004;23(4):319-31. [pmid: 15838815].
29 Ozerdogan N, Beji NK, Yalcin O. Urinary incontinence: its prevalence, risk factors and effects on the quality of life of women living in a region of Turkey. Gynecol Obstet Invest. 2004;58(3):145-50. [pmid: 15237249].
30 Schytt E, Lindmark G, Waldenstrom U. Symptoms of stress incontinence 1 year after childbirth: prevalence and predictors in a national Swedish sample. Acta Obstet Gynecol Scand. Oct. 2004;83(10):928-36. [pmid: 15453888].
31 de Tayrac R, Chevalier N, Chauveaud-Lambling A, et al. Risk of urge and stress urinary incontinence at long-term follow-up after vaginal hysterectomy. Am J Obstet Gynecol. Jul. 2004;191(1):90-4. [pmid: 15295347].
32 Hu JC, Gold KF, Pashos CL, et al. Temporal trends in radical prostatectomy complications from 1991 to 1998. J Urol. Apr. 2003;169(4):1443-8. [pmid: 12629380].
33 Long CY, Hsu SC, Wu TP, et al. Effect of laparoscopic hysterectomy on bladder neck and urinary symptoms. Aust N Z J Obstet Gynaecol. Feb. 2003;43(1):65-9. [pmid: 12755352].
34 Yip SK, Sahota D, Chang A, et al. Effect of one interval vaginal delivery on the prevalence of stress urinary incontinence: a prospective cohort study. Neurourol Urodyn. 2003;22(6):558-62. [pmid: 12951663].
35 Kjerulff KH, Langenberg PW, Greenaway L, et al. Urinary incontinence and hysterectomy in a large prospective cohort study in American women. J Urol. May. 2002;167(5):2088-92. [pmid: 11956446].
36 Viktrup L. The risk of lower urinary tract symptoms five years after the first delivery. Neurourol Urodyn. 2002;21(1):2-29. [pmid: 11835420].
37 Moller LA, Lose G, Jorgensen T. Incidence and remission rates of lower urinary tract symptoms at one year in women aged 40–60: longitudinal study. BMJ. May 27. 2000;320(7247):1429-32. [pmid: 10827042]. [pmcid: 27383].
38 Samuelsson EC, Victor FT, Svardsudd KF. Five-year incidence and remission rates of female urinary incontinence in a Swedish population less than 65 years old. Am J Obstet Gynecol. Sep. 2000;183(3):568-74. [pmid: 10992175].
39 Hojberg KE, Salvig JD, Winslow NA, et al. Urinary incontinence: prevalence and risk factors at 16 weeks of gestation. Br J Obstet Gynaecol. Aug. 1999;106(8):842-50. [pmid: 10453836].
40 Sgadari A, Topinkova E, Bjornson J, et al. Urinary incontinence in nursing home residents: a cross-national comparison. Age Ageing. Sep. 1997;26(Suppl 2):49-54. [pmid: 9464555].
41 Herzog AR, Diokno AC, Brown MB, et al. Two-year incidence, remission, and change patterns of urinary incontinence in noninstitutionalized older adults. J Gerontol. Mar. 1990;45(2):M67-74. [pmid: 2313045].
42 Bluestein D, Rutledge CM. Perceived health and geriatric risk stratification: observations from family practice. Can Fam Physician. May. 2006;52:626-7. [pmid: 17327894]. [pmcid: 1531732].
43 Boyington JE, Howard DL, Carter-Edwards L, et al. Differences in resident characteristics and prevalence of urinary incontinence in nursing homes in the southeastern United States. Nurs Res. Mar–Apr. 2007;56(2):97-107. [pmid: 17356440].
44 Danforth KN, Shah AD, Townsend MK, et al. Physical activity and urinary incontinence among healthy, older women. Obstet Gynecol. Mar. 2007;109(3):721-7. [pmid: 17329526].
45 Goldacre MJ, Abisgold JD, Yeates DG, et al. Self-harm and depression in women with urinary incontinence: a record-linkage study. BJU Int. Mar. 2007;99(3):601-5. [pmid: 17155988].
46 Huang AJ, Brown JS, Thom DH, et al. Urinary incontinence in older community-dwelling women: the role of cognitive and physical function decline. Obstet Gynecol. Apr. 2007;109(4):909-16. [pmid: 17400853].
47 Jacobsen NE, Moore KN, Estey E, et al. Open versus laparoscopic radical prostatectomy: a prospective comparison of postoperative urinary incontinence rates. J Urol. Feb. 2007;177(2):615-9. [pmid: 17222646].
48 Smither AR, Guralnick ML, Davis NB, et al. Quantifying the natural history of post-radical prostatectomy incontinence using objective pad test data. BMC Urol. 2007;7:2. [pmid: 17280607]. [pmcid: 1800860].
49 Waetjen LE, Liao S, Johnson WO, et al. Factors associated with prevalent and incident urinary incontinence in a cohort of midlife women: a longitudinal analysis of data: study of women's health across the nation. Am J Epidemiol. Feb 1. 2007;165(3):309-18. [pmid: 17132698].
50 Adelmann PK. Prevalence and detection of urinary incontinence among older Medicaid recipients. J Health Care Poor Underserved. Feb. 2004;15(1):99-112. [pmid: 15359977].
51 Foldspang A, Hvidman L, Mommsen S, et al. Risk of postpartum urinary incontinence associated with pregnancy and mode of delivery. Acta Obstet Gynecol Scand. Oct. 2004;83(10):923-7. [pmid: 15453887].
52 Fritel X, Fauconnier A, Levet C, et al. Stress urinary incontinence 4 years after the first delivery: a retrospective cohort survey. Acta Obstet Gynecol Scand. Oct. 2004;83(10):941-5. [pmid: 15453890].
53 Groutz A, Rimon E, Peled S, et al. Cesarean section: does it really prevent the development of postpartum stress urinary incontinence? A prospective study of 363 women one year after their first delivery. Neurourol Urodyn. 2004;23(1):2-6. [pmid: 14694448].
54 Stenzelius K, Mattiasson A, Hallberg IR, et al. Symptoms of urinary and faecal incontinence among men and women 75+ in relations to health complaints and quality of life. Neurourol Urodyn. 2004;23(3):211-22. [pmid: 15098216].
55 Vandoninck V, Bemelmans BL, Mazzetta C, et al. The prevalence of urinary incontinence in community-dwelling married women: a matter of definition. BJU Int. Dec. 2004;94(9):1291-5. [pmid: 15610108].
56 Arya LA, Jackson ND, Myers DL, et al. Risk of new-onset urinary incontinence after forceps and vacuum delivery in primiparous women. Am J Obstet Gynecol. Dec. 2001;185(6):1318-23. discussion 23–4. [pmid: 11744903].
57 Sherburn M, Guthrie JR, Dudley EC, et al. Is incontinence associated with menopause?. Obstet Gynecol. Oct. 2001;98(4):628-33. [pmid: 11576579].
58 Van Kessel K, Reed S, Newton K, et al. The second stage of labor and stress urinary incontinence. Am J Obstet Gynecol. Jun. 2001;184(7):1571-5. [pmid: 11408883].
59 Larrieu S, Peres K, Letenneur L, et al. Relationship between body mass index and different domains of disability in older persons: the 3C study. Int J Obes Relat Metab Disord. Dec. 2004;28(12):1555-60. [pmid: 15314627].
60 Viktrup L, Lose G, Rolff M, et al. The symptom of stress incontinence caused by pregnancy or delivery in primiparas. Obstet Gynecol. Jun. 1992;79(6):945-9. [pmid: 1579319].
61 van Kuijk AA, van der Linde H, van Limbeek J. Urinary incontinence in stroke patients after admission to a postacute inpatient rehabilitation program. Arch Phys Med Rehabil. Oct. 2001;82(10):1407-11. [pmid: 11588745].
62 Schmidbauer J, Temml C, Schatzl G, et al. Risk factors for urinary incontinence in both sexes. Analysis of a health screening project. Eur Urol. May. 2001;39(5):565-70. [pmid: 11464038].
63 Hu KK, Boyko EJ, Scholes D, et al. Risk factors for urinary tract infections in postmenopausal women. Arch Intern Med. May 10. 2004;164(9):989-93. [pmid: 15136308].
64 Bradley CS, Kennedy CM, Nygaard IE. Pelvic floor symptoms and lifestyle factors in older women. J Womens Health (Larchmt). Mar. 2005;14(2):128-36. [pmid: 15775730].
65 O'Donnell M, Lose G, Sykes D, et al. Help-seeking behaviour and associated factors among women with urinary incontinence in France, Germany, Spain and the United Kingdom. Eur Urol. Mar. 2005;47(3):385-92. discussion 92. [pmid: 15716205].
66 Samuelsson E, Victor A, Svardsudd K. Determinants of urinary incontinence in a population of young and middle-aged women. Acta Obstet Gynecol Scand. Mar. 2000;79(3):208-15. [pmid: 10716302].
67 MacArthur C, Glazener CM, Wilson PD, et al. Persistent urinary incontinence and delivery mode history: a six-year longitudinal study. Bjog. Feb. 2006;113(2):218-24. [pmid: 16412001].
68 Danforth KN, Townsend MK, Lifford K, et al. Risk factors for urinary incontinence among middle-aged women. Am J Obstet Gynecol. Feb. 2006;194(2):339-45. [pmid: 16458626]. [pmcid: 1363686].
69 Huang AJ, Brown JS, Kanaya AM, et al. Quality-of-life impact and treatment of urinary incontinence in ethnically diverse older women. Arch Intern Med. Oct 9. 2006;166(18):2000-6. [pmid: 17030834].
70 Huang AJ, Thom DH, Kanaya AM, et al. Urinary incontinence and pelvic floor dysfunction in Asian-American women. Am J Obstet Gynecol. Nov. 2006;195(5):1331-7. [pmid: 16643821]. [pmcid: 1630451].
71 Fitzgerald MP, Thom DH, Wassel-Fyr C, et al. Childhood urinary symptoms predict adult overactive bladder symptoms. J Urol. Mar. 2006;175(3 Pt 1):989-93. [pmid: 16469599]. [pmcid: 1820589].
72 Hatem M, Fraser W, Lepire E. Postpartum urinary and anal incontinence: a population-based study of quality of life of primiparous women in Quebec. J Obstet Gynaecol Can. Jul. 2005;27(7):682-8. [pmid: 16100623].
73 Lewis CM, Schrader R, Many A, et al. Diabetes and urinary incontinence in 50- to 90-year-old women: a cross-sectional population-based study. Am J Obstet Gynecol. Dec. 2005;193(6):2154-8. [pmid: 16325633].
74 Rait G, Fletcher A, Smeeth L, et al. Prevalence of cognitive impairment: results from the MRC trial of assessment and management of older people in the community. Age Ageing. May. 2005;34(3):242-8. [pmid: 15863409].
75 Tellez-Zenteno JF, Matijevic S, Wiebe S. Somatic comorbidity of epilepsy in the general population in Canada. Epilepsia. Dec. 2005;46(12):1955-62. [pmid: 16393162].
76 Ertunc D, Tok EC, Pata O, et al. Is stress urinary incontinence a familial condition?. Acta Obstet Gynecol Scand. Oct. 2004;83(10):912-6. [pmid: 15453885].
77 Hannestad YS, Lie RT, Rortveit G, et al. Familial risk of urinary incontinence in women: population based cross sectional study. Bmj. Oct 16. 2004;329(7471):889-91. [pmid: 15485965]. [pmcid: 523112].
78 Rohr G, Kragstrup J, Gaist D, et al. Genetic and environmental influences on urinary incontinence: a Danish population-based twin study of middle-aged and elderly women. Acta Obstet Gynecol Scand. Oct. 2004;83(10):978-82. [pmid: 15453898].
79 Nygaard I, Turvey C, Burns TL, et al. Urinary incontinence and depression in middle-aged United States women. Obstet Gynecol. Jan. 2003;101(1):149-56. [pmid: 12517660].
80 Aaron R, Muliyil J, Abraham S. Medico-social dimensions of menopause: a cross-sectional study from rural south India. Natl Med J India. Jan–Feb. 2002;15(1):14-7. [pmid: 11855585].
81 Fitzgerald ST, Palmer MH, Kirkland VL, et al. The impact of urinary incontinence in working women: a study in a production facility. Women Health. 2002;35(1):1-16. [pmid: 11942466].
82 Langa KM, Fultz NH, Saint S, et al. Informal caregiving time and costs for urinary incontinence in older individuals in the United States. J Am Geriatr Soc. Apr. 2002;50(4):733-7. [pmid: 11982676].
83 Nuotio M, Tammela TL, Luukkaala T, et al. Urgency and urge incontinence in an older population: ten-year changes and their association with mortality. Aging Clin Exp Res. Oct. 2002;14(5):412-9. [pmid: 12602577].
84 MacLennan AH, Taylor AW, Wilson DH, et al. The prevalence of pelvic floor disorders and their relationship to gender, age, parity and mode of delivery. Bjog. Dec. 2000;107(12):1460-70. [pmid: 11192101].
85 Hagglund D, Olsson H, Leppert J. Urinary incontinence: an unexpected large problem among young females. Results from a population-based study. Fam Pract. Oct. 1999;16(5):506-9. [pmid: 10533948].
86 Palmer MH, Fitzgerald S, Berry SJ, et al. Urinary incontinence in working women: an exploratory study. Women Health. 1999;29(3):67-82. [pmid: 10466511].
87 Roe B, Doll H. Lifestyle factors and continence status: Comparison of self-report data from a postal survey in England. J WOCN. 1999;26:312-9.
88 Mushkat Y, Bukovsky I, Langer R. Female urinary stress incontinence—does it have familial prevalence?. Am J Obstet Gynecol. Feb. 1996;174(2):617-9. [pmid: 8623794].
89 Diokno AC, Estanol MV, Ibrahim IA, et al. Prevalence of urinary incontinence in community dwelling men: a cross sectional nationwide epidemiological survey. Int Urol Nephrol. 2007;39(1):129-36. [pmid: 17086446].
90 Kinchen KS, Lee J, Fireman B, et al. The prevalence, burden, and treatment of urinary incontinence among women in a managed care plan. J Womens Health (Larchmt). Apr. 2007;16(3):415-22. [pmid: 17439386].
91 Altman D, Zetterstrom J, Schultz I, et al. Pelvic organ prolapse and urinary incontinence in women with surgically managed rectal prolapse: a population-based case-control study. Dis Colon Rectum. Jan. 2006;49(1):28-35. [pmid: 16273329].
92 Anger JT, Saigal CS, Litwin MS. The prevalence of urinary incontinence among community dwelling adult women: results from the National Health and Nutrition Examination Survey. J Urol. Feb. 2006;175(2):601-4. [pmid: 16407004].
93 Anger JT, Saigal CS, Pace J, et al. True prevalence of urinary incontinence among female nursing home residents. Urology. Feb. 2006;67(2):281-7. [pmid: 16461078].
94 Anger JT, Saigal CS, Stothers L, et al. The prevalence of urinary incontinence among community dwelling men: results from the National Health and Nutrition Examination survey. J Urol. Nov. 2006;176(5):2103-8. discussion 8. [pmid: 17070268].
95 Brown JS, Vittinghoff E, Lin F, et al. Prevalence and risk factors for urinary incontinence in women with type 2 diabetes and impaired fasting glucose: findings from the National Health and Nutrition Examination Survey (NHANES) 2001-2002. Diabetes Care. Jun. 2006;29(6):1307-12. [pmid: 16732013]. [pmcid: 1557358].
96 Irwin DE, Milsom I, Hunskaar S, et al. Population-based survey of urinary incontinence, overactive bladder, and other lower urinary tract symptoms in five countries: results of the EPIC study. Eur Urol. Dec. 2006;50(6):1306-14. discussion 14–5. [pmid: 17049716].
97 Lewinshtein DJ, Perrotte P, Lebeau T, et al. Normal urinary and sexual function in men without evidence of prostate cancer from Montreal, Canada. BJU Int. Jun. 2006;97(6):1273-7. [pmid: 16686725].
98 Mardon RE, Halim S, Pawlson LG, et al. Management of urinary incontinence in Medicare managed care beneficiaries: results from the 2004 Medicare Health Outcomes Survey. Arch Intern Med. May 22. 2006;166(10):1128-33. [pmid: 16717176].
99 Thom DH, van den Eeden SK, Ragins AI, et al. Differences in prevalence of urinary incontinence by race/ethnicity. J Urol. Jan. 2006;175(1):259-64. [pmid: 16406923]. [pmcid: 1557354].
100 Jackson SL, Scholes D, Boyko EJ, et al. Predictors of urinary incontinence in a prospective cohort of postmenopausal women. Obstet Gynecol. Oct. 2006;108(4):855-62. [pmid: 17012446].
101 Jackson SL, Scholes D, Boyko EJ, et al. Urinary incontinence and diabetes in postmenopausal women. Diabetes Care. Jul. 2005;28(7):1730-8. [pmid: 15983327].
102 Lukacz ES, Lawrence JM, Contreras R, et al. Parity, mode of delivery, and pelvic floor disorders. Obstet Gynecol. Jun. 2006;107(6):1253-60. [pmid: 16738149].
103 Tannenbaum C, Corcos J, Assalian P. The relationship between sexual activity and urinary incontinence in older women. J Am Geriatr Soc. Aug. 2006;54(8):1220-4. [pmid: 16913988].
104 Viktrup L, Rortveit G, Lose G. Risk of stress urinary incontinence twelve years after the first pregnancy and delivery. Obstet Gynecol. Aug. 2006;108(2):248-54. [pmid: 16880292].
105 Teleman P, Lidfeldt J, Nerbrand C, et al. Lower urinary tract symptoms in middle-aged women—prevalence and attitude towards mild urinary incontinence: a community-based population study. Acta Obstet Gynecol Scand. Nov. 2005;84(11):1108-12. [pmid: 16232181].
106 Swanson JG, Kaczorowski J, Skelly J, et al. Urinary incontinence: common problem among women over 45. Can Fam Physician. Jan. 2005;51:84-5. [pmid: 16926957]. [pmcid: 1479575].
107 Rohr G, Stovring H, Christensen K, et al. Characteristics of middle-aged and elderly women with urinary incontinence. Scand J Prim Health Care. Dec. 2005;23(4):203-8. [pmid: 16272067].
108 Ruff CC. Risk factors for urinary incontinence in African-American women. Urol Nurs. Feb. 2005;25(1):33-9. [pmid: 15779690].
109 Lifford KL, Curhan GC, Hu FB, et al. Type 2 diabetes mellitus and risk of developing urinary incontinence. J Am Geriatr Soc. Nov. 2005;53(11):1851-7. [pmid: 16274364].
110 Fritel X, Ringa V, Varnoux N, et al. Mode of delivery and severe stress incontinence. a cross-sectional study among 2,625 perimenopausal women. Bjog. Dec. 2005;112(12):1646-51. [pmid: 16305569].
111 Oskay UY, Beji NK, Yalcin O. A study on urogenital complaints of postmenopausal women aged 50 and over. Acta Obstet Gynecol Scand. Jan. 2005;84(1):72-8. [pmid: 15603571].
112 Melville JL, Katon W, Delaney K, et al. Urinary incontinence in US women: a population-based study. Arch Intern Med. Mar 14. 2005;165(5):537-42. [pmid: 15767530].
113 Homma Y, Yamaguchi O, Hayashi K. An epidemiological survey of overactive bladder symptoms in Japan. BJU Int. Dec. 2005;96(9):1314-8. [pmid: 16287452].
114 Jorgensen L, Engstad T, Jacobsen BK. Self-reported urinary incontinence in noninstitutionalized long-term stroke survivors: A population-based study. Arch Phys Med Rehabil. Mar. 2005;86(3):416-20. [pmid: 15759221].
115 Jumadilova Z, Zyczynski T, Paul B, et al. Urinary incontinence in the nursing home: resident characteristics and prevalence of drug treatment. Am J Manag Care. Jul. 2005;11(4 Suppl):S112-20. [pmid: 16161384].
116 Stothers L, Thom D, Calhoun E. Urologic diseases in America project: urinary incontinence in males—demographics and economic burden. J Urol. Apr. 2005;173(4):1302-8. [pmid: 15758786].
117 Tegerstedt G, Maehle-Schmidt M, Nyren O, et al. Prevalence of symptomatic pelvic organ prolapse in a Swedish population. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):497-503. [pmid: 15986100].
118 Moorthy P, Lapitan MC, Quek PL, et al. Prevalence of overactive bladder in Asian men: an epidemiological survey. BJU Int. Mar. 2004;93(4):528-31. [pmid: 15008723].
119 Teunissen TA, van den Bosch WJ, van den Hoogen HJ, et al. Prevalence of urinary, fecal and double incontinence in the elderly living at home. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):10-3. discussion 3. [pmid: 14752592].
120 Araki I, Zakoji H, Komuro M, et al. Lower urinary tract symptoms in men and women without underlying disease causing micturition disorder: a cross-sectional study assessing the natural history of bladder function. J Urol. Nov. 2003;170(5):1901-4. [pmid: 14532803].
121 Boyle P, Robertson C, Mazzetta C, et al. The prevalence of male urinary incontinence in four centres: the UREPIK study. BJU Int. Dec. 2003;92(9):943-7. [pmid: 14632852].
122 Burgio KL, Zyczynski H, Locher JL, et al. Urinary incontinence in the 12-month postpartum period. Obstet Gynecol. Dec. 2003;102(6):1291-8. [pmid: 14662217].
123 Chen GD, Lin TL, Hu SW, et al. Prevalence and correlation of urinary incontinence and overactive bladder in Taiwanese women. Neurourol Urodyn. 2003;22(2):109-17. [pmid: 12579627].
124 Chen YC, Chen GD, Hu SW, et al. Is the occurrence of storage and voiding dysfunction affected by menopausal transition or associated with the normal aging process?. Menopause. May–Jun. 2003;10(3):203-8. [pmid: 12792290].
125 Engstrom G, Walker-Engstrom ML, Loof L, et al. Prevalence of three lower urinary tract symptoms in men-a population-based study. Fam Pract. Feb. 2003;20(1):7-10. [pmid: 12509363].
126 Espino DV, Palmer RF, Miles TP, et al. Prevalence and severity of urinary incontinence in elderly Mexican-American women. J Am Geriatr Soc. Nov. 2003;51(11):1580-6. [pmid: 14687387].
127 Eva UF, Gun W, Preben K. Prevalence of urinary and fecal incontinence and symptoms of genital prolapse in women. Acta Obstet Gynecol Scand. Mar. 2003;82(3):280-6. [pmid: 12694126].
128 Goldberg RP, Kwon C, Gandhi S, et al. Urinary incontinence among mothers of multiples: the protective effect of cesarean delivery. Am J Obstet Gynecol. Jun. 2003;188(6):1447-50. discussion 50–3. [pmid: 12824977].
129 Grodstein F, Fretts R, Lifford K, et al. Association of age, race, and obstetric history with urinary symptoms among women in the Nurses' Health Study. Am J Obstet Gynecol. Aug. 2003;189(2):428-34. [pmid: 14520212].
130 Hvidman L, Foldspang A, Mommsen S, et al. Postpartum urinary incontinence. Acta Obstet Gynecol Scand. Jun. 2003;82(6):556-63. [pmid: 12780427].
131 Landi F, Cesari M, Russo A, et al. Potentially reversible risk factors and urinary incontinence in frail older people living in community. Age Ageing. Mar. 2003;32(2):194-9. [pmid: 12615564].
132 Maffezzini M, Seveso M, Taverna G, et al. Evaluation of complications and results in a contemporary series of 300 consecutive radical retropubic prostatectomies with the anatomic approach at a single institution. Urology. May. 2003;61(5):982-6. [pmid: 12736020].
133 Mawajdeh SM, Al-Qutob R, Schmidt A. Measuring reproductive morbidity: a community-based approach, Jordan. Health Care Women Int. Aug. 2003;24(7):635-49. [pmid: 14627210].
134 Miller YD, Brown WJ, Russell A, et al. Urinary incontinence across the lifespan. Neurourol Urodyn. 2003;22(6):550-7. [pmid: 12951662].
135 Miller YD, Brown WJ, Smith N, et al. Managing urinary incontinence across the lifespan. Int J Behav Med. 2003;10(2):143-61. [pmid: 12763707].
136 Nuotio M, Jylha M, Luukkaala T, et al. Urinary incontinence in a Finnish population aged 70 and over. Prevalence of types, associated factors and self-reported treatments. Scand J Prim Health Care. Sep. 2003;21(3):182-7. [pmid: 14531512].
137 Nuotio M, Tammela TL, Luukkaala T, et al. Predictors of institutionalization in an older population during a 13-year period: the effect of urge incontinence. J Gerontol A Biol Sci Med Sci. Aug. 2003;58(8):756-62. [pmid: 12902536].
138 Parazzini F, Chiaffarino F, Lavezzari M, et al. Risk factors for stress, urge or mixed urinary incontinence in Italy. Bjog. Oct. 2003;110(10):927-33. [pmid: 14550363].
139 Peters TJ, Horrocks S, Stoddart H, et al. Factors associated with variations in older people's use of community-based continence services. Health Soc Care Community. Jan. 2004;12(1):53-62. [pmid: 14675365].
140 Rortveit G, Daltveit AK, Hannestad YS, et al. Urinary incontinence after vaginal delivery or cesarean section. N Engl J Med. Mar 6. 2003;348(10):900-7. [pmid: 12621134].
141 Stewart WF, Van Rooyen JB, Cundiff GW, et al. Prevalence and burden of overactive bladder in the United States. World J Urol. May. 2003;20(6):327-36. [pmid: 12811491].
142 Talcott JA, Manola J, Clark JA, et al. Time course and predictors of symptoms after primary prostate cancer therapy. J Clin Oncol. Nov 1. 2003;21(21):3979-86. [pmid: 14581420].
143 Bogner HR, Gallo JJ, Sammel MD, et al. Urinary incontinence and psychological distress in community-dwelling older adults. J Am Geriatr Soc. Mar. 2002;50(3):489-95. [pmid: 11943045].
144 Buchsbaum GM, Chin M, Glantz C, et al. Prevalence of urinary incontinence and associated risk factors in a cohort of nuns. Obstet Gynecol. Aug. 2002;100(2):226-9. [pmid: 12151141].
145 Finkelstein MM. Medical conditions, medications, and urinary incontinence. Analysis of a population-based survey. Can Fam Physician. Jan. 2002;48:96-101. [pmid: 11852617]. [pmcid: 2213925].
146 Landi F, Cesari M, Russo A, et al. Benzodiazepines and the risk of urinary incontinence in frail older persons living in the community. Clin Pharmacol Ther. Dec. 2002;72(6):729-34. [pmid: 12496754].
147 Liu C, Andrews GR. Prevalence and incidence of urinary incontinence in the elderly: a longitudinal study in South Australia. Chin Med J (Engl). Jan. 2002;115(1):119-22. [pmid: 11930643].
148 Nuotio M, Jylha M, Luukkaala T, et al. Urgency, urge incontinence and voiding symptoms in men and women aged 70 years and over. BJU Int. Mar. 2002;89(4):350-5. [pmid: 11872023].
149 Peyrat L, Haillot O, Bruyere F, et al. Prevalence and risk factors of urinary incontinence in young and middle-aged women. BJU Int. Jan. 2002;89(1):61-6. [pmid: 11849162].
150 Pregazzi R, Sartore A, Troiano L, et al. Postpartum urinary symptoms: prevalence and risk factors. Eur J Obstet Gynecol Reprod Biol. Jul 10. 2002;103(2):179-82. [pmid: 12069744].
151 Sampselle CM, Harlow SD, Skurnick J, et al. Urinary incontinence predictors and life impact in ethnically diverse perimenopausal women. Obstet Gynecol. Dec. 2002;100(6):1230-8. [pmid: 12468167].
152 Sebesta M, Cespedes RD, Luhman E, et al. Questionnaire-based outcomes of urinary incontinence and satisfaction rates after radical prostatectomy in a national study population. Urology. Dec. 2002;60(6):1055-8. [pmid: 12475669].
153 Sze EH, Jones WP, Ferguson JL, et al. Prevalence of urinary incontinence symptoms among black, white, and Hispanic women. Obstet Gynecol. Apr. 2002;99(4):572-5. [pmid: 12039113].
154 Thompson JF, Roberts CL, Currie M, et al. Prevalence and persistence of health problems after childbirth: associations with parity and method of birth. Birth. Jun. 2002;29(2):83-94. [pmid: 12051189].
155 van der Vaart CH, van der Bom JG, de Leeuw JR, et al. The contribution of hysterectomy to the occurrence of urge and stress urinary incontinence symptoms. Bjog. Feb. 2002;109(2):149-54. [pmid: 11911100].
156 van der Vaart CH, de Leeuw JR, Roovers JP, et al. The effect of urinary incontinence and overactive bladder symptoms on quality of life in young women. BJU Int. Oct. 2002;90(6):544-9. [pmid: 12230614].
157 Van Oyen H, Van Oyen P. Urinary incontinence in Belgium; prevalence, correlates and psychosocial consequences. Acta Clin Belg. Jul–Aug. 2002;57(4):207-18. [pmid: 12462797].
158 Maggi S, Minicuci N, Langlois J, et al. Prevalence rate of urinary incontinence in community-dwelling elderly individuals: the Veneto study. J Gerontol A Biol Sci Med Sci. Jan. 2001;56(1):M14-8. [pmid: 11193226].
159 Maral I, Ozkardes H, Peskircioglu L, et al. Prevalence of stress urinary incontinence in both sexes at or after age 15 years: a cross-sectional study. J Urol. Feb. 2001;165(2):408-12. [pmid: 11176384].
160 Muscatello DJ, Rissel C, Szonyi G. Urinary symptoms and incontinence in an urban community: prevalence and associated factors in older men and women. Intern Med J. Apr. 2001;31(3):151-60. [pmid: 11478344].
161 Patel M, Coshall C, Lawrence E, et al. Recovery from poststroke urinary incontinence: associated factors and impact on outcome. J Am Geriatr Soc. Sep. 2001;49(9):1229-33. [pmid: 11559384].
162 Stoddart H, Donovan J, Whitley E, et al. Urinary incontinence in older people in the community: a neglected problem?. Br J Gen Pract. Jul. 2001;51(468):548-52. [pmid: 11462314]. [pmcid: 1314046].
163 Aggazzotti G, Pesce F, Grassi D, et al. Prevalence of urinary incontinence among institutionalized patients: a cross-sectional epidemiologic study in a midsized city in northern Italy. Urology. Aug 1. 2000;56(2):245-9. [pmid: 10925087].
164 Alling Moller L, Lose G, Jorgensen T. Risk factors for lower urinary tract symptoms in women 40 to 60 years of age. Obstet Gynecol. Sep. 2000;96(3):446-51. [pmid: 10960640].
165 Bortolotti A, Bernardini B, Colli E, et al. Prevalence and risk factors for urinary incontinence in Italy. Eur Urol. Jan. 2000;37(1):30-5. [pmid: 10671782].
166 Hannestad YS, Rortveit G, Sandvik H, et al. A community-based epidemiological survey of female urinary incontinence: the Norwegian EPINCONT study. Epidemiology of Incontinence in the County of Nord-Trondelag. J Clin Epidemiol. Nov. 2000;53(11):1150-7. [pmid: 11106889].
167 Gavira Iglesias FJ, Caridad y Ocerin JM, Perez del Molino Martin J, et al. Prevalence and psychosocial impact of urinary incontinence in older people of a Spanish rural population. J Gerontol A Biol Sci Med Sci. Apr. 2000;55(4):M207-14. [pmid: 10811150].
168 Roe B, Doll H. Prevalence of urinary incontinence and its relationship with health status. J Clin Nurs. Mar. 2000;9(2):178-87. [pmid: 11111607].
169 Smoger SH, Felice TL, Kloecker GH. Urinary incontinence among male veterans receiving care in primary care clinics. Ann Intern Med. Apr 4. 2000;132(7):547-51. [pmid: 10744591].
170 Temml C, Haidinger G, Schmidbauer J, et al. Urinary incontinence in both sexes: prevalence rates and impact on quality of life and sexual life. Neurourol Urodyn. 2000;19(3):259-71. [pmid: 10797583].
171 Tseng IJ, Chen YT, Chen MT, et al. Prevalence of urinary incontinence and intention to seek treatment in the elderly. J Formos Med Assoc. Oct. 2000;99(10):753-8. [pmid: 11061069].
172 Ueda T, Tamaki M, Kageyama S, et al. Urinary incontinence among community-dwelling people aged 40 years or older in Japan: prevalence, risk factors, knowledge and self-perception. Int J Urol. Mar. 2000;7(3):95-103. [pmid: 10750888].
173 Chiarelli P, Brown W, McElduff P. Leaking urine: prevalence and associated factors in Australian women. Neurourol Urodyn. 1999;18(6):567-77. [pmid: 10529705].
174 Dolan LM, Casson K, McDonald P, et al. Urinary incontinence in Northern Ireland: a prevalence study. BJU Int. May. 1999;83(7):760-6. [pmid: 10368192].
175 Foldspang A, Mommsen S, Djurhuus JC. Prevalent urinary incontinence as a correlate of pregnancy, vaginal childbirth, and obstetric techniques. Am J Public Health. Feb. 1999;89(2):209-12. [pmid: 9949751]. [pmcid: 1508519].
176 Damian J, Martin-Moreno JM, Lobo F, et al. Prevalence of urinary incontinence among Spanish older people living at home. Eur Urol. Oct. 1998;34(4):333-8. [pmid: 9748681].
177 Koyama W, Koyanagi A, Mihara S, et al. Prevalence and conditions of urinary incontinence among the elderly. Methods Inf Med. Jun. 1998;37(2):151-5. [pmid: 9656656].
178 Koskimaki J, Hakama M, Huhtala H, et al. Prevalence of lower urinary tract symptoms in Finnish men: a population-based study. Br J Urol. Mar. 1998;81(3):364-9. [pmid: 9523653].
179 Kuh D, Cardozo L, Hardy R. Urinary incontinence in middle aged women: childhood enuresis and other lifetime risk factors in a British prospective cohort. J Epidemiol Community Health. Aug. 1999;53(8):453-8. [pmid: 10562862]. [pmcid: 1756946].
180 Stenberg A, Heimer G, Holmberg L, et al. Prevalence of postmenopausal symptoms in two age groups of elderly women in relation to oestrogen replacement therapy. Maturitas. Dec 15. 1999;33(3):229-37. [pmid: 10656501].
181 Swithinbank LV, Donovan JL, du Heaume JC, et al. Urinary symptoms and incontinence in women: relationships between occurrence, age, and perceived impact. Br J Gen Pract. Nov. 1999;49(448):897-900. [pmid: 10818656]. [pmcid: 1313561].
182 Jitapunkul S, Khovidhunkit W. Urinary incontinence in Thai elderly living in Klong Toey slum. J Med Assoc Thai. Mar. 1998;81(3):160-8. [pmid: 9623006].
183 Roberts RO, Jacobsen SJ, Rhodes T, et al. Urinary incontinence in a community-based cohort: prevalence and healthcare-seeking. J Am Geriatr Soc. Apr. 1998;46(4):467-72. [pmid: 9560070].
184 Talcott JA, Rieker P, Clark JA, et al. Patient-reported symptoms after primary therapy for early prostate cancer: results of a prospective cohort study. J Clin Oncol. Jan. 1998;16(1):275-83. [pmid: 9440753].
185 Bogren MA, Hvarfwen E, Fridlund B. Urinary incontinence among a 65-year old Swedish population: medical history and psychosocial consequences. Vard Nord Utveckl Forsk. Winter. 1997;17(4):14-7.
186 Brandeis GH, Baumann MM, Hossain M, et al. The prevalence of potentially remediable urinary incontinence in frail older people: a study using the Minimum Data Set. J Am Geriatr Soc. Feb. 1997;45(2):179-84. [pmid: 9033516].
187 Brieger GM, Mongelli M, Hin LY, et al. The epidemiology of urinary dysfunction in Chinese women. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):191-5. [pmid: 9449294].
188 Malmsten UG, Milsom I, Molander U, et al. Urinary incontinence and lower urinary tract symptoms: an epidemiological study of men aged 45 to 99 years. J Urol. Nov. 1997;158(5):1733-7. [pmid: 9334589].
189 Mozes B, Shmueli A. Underutilization of health services among patients with urinary symptoms: results of a population-based survey in Israel. Prostate. Dec 1. 1997;33(4):246-51. [pmid: 9397196].
190 Nakanishi N, Tatara K, Naramura H, et al. Urinary and fecal incontinence in a community-residing older population in Japan. J Am Geriatr Soc. Feb. 1997;45(2):215-9. [pmid: 9033523].
191 Samuelsson E, Victor A, Tibblin G. A population study of urinary incontinence and nocturia among women aged 20–59 years. Prevalence, well-being and wish for treatment. Acta Obstet Gynecol Scand. Jan. 1997;76(1):74-80. [pmid: 9033249].
192 Schulman C, Claes H, Matthijs J. Urinary incontinence in Belgium: a population-based epidemiological survey. Eur Urol. 1997;32(3):315-20. [pmid: 9358220].
193 Thom DH, van den Eeden SK, Brown JS. Evaluation of parturition and other reproductive variables as risk factors for urinary incontinence in later life. Obstet Gynecol. Dec. 1997;90(6):983-9. [pmid: 9397116].
194 Brown JS, Seeley DG, Fong J, et al. Urinary incontinence in older women: who is at risk? Study of Osteoporotic Fractures Research Group. Obstet Gynecol. May. 1996;87(5 Pt 1):715-21. [pmid: 8677073].
195 Umlauf MG, Sherman SM. Symptoms of urinary incontinence among older community-dwelling men. J Wound Ostomy Continence Nurs. Nov. 1996;23(6):314-21. [pmid: 9043282].
196 Seim A, Sandvik H, Hermstad R, et al. Female urinary incontinence—consultation behaviour and patient experiences: an epidemiological survey in a Norwegian community. Fam Pract. Mar. 1995;12(1):18-21. [pmid: 7665034].
197 Kutner NG, Schechtman KB, Ory MG, et al. Older adults' perceptions of their health and functioning in relation to sleep disturbance, falling, and urinary incontinence.FICSIT Group. J Am Geriatr Soc. Jul. 1994;42(7):757-62. [pmid: 8014352].
198 Mommsen S, Foldspang A. Body mass index and adult female urinary incontinence. World J Urol. 1994;12(6):319-22. [pmid: 7881469].
199 Brocklehurst JC. Urinary incontinence in the community—analysis of a MORI poll. BMJ. Mar 27. 1993;306(6881):832-4. [pmid: 8490377]. [pmcid: 1677310].
200 Lagace EA, Hansen W, Hickner JM. Prevalence and severity of urinary incontinence in ambulatory adults: an UPRNet study. J Fam Pract. Jun. 1993;36(6):610-4. [pmid: 8505603].
201 Milsom I, Ekelund P, Molander U, et al. The influence of age, parity, oral contraception, hysterectomy and menopause on the prevalence of urinary incontinence in women. J Urol. Jun. 1993;149(6):1459-62. [pmid: 8501788].
202 Kok AL, Voorhorst FJ, Burger CW, et al. Urinary and faecal incontinence in community-residing elderly women. Age Ageing. May. 1992;21(3):211-5. [pmid: 1615785].
203 Rekers H, Drogendijk AC, Valkenburg HA, et al. The menopause, urinary incontinence and other symptoms of the genito-urinary tract. Maturitas. Oct. 1992;15(2):101-11. [pmid: 1470043].
204 Burgio KL, Matthews KA, Engel BT. Prevalence, incidence and correlates of urinary incontinence in healthy, middle-aged women. J Urol. Nov. 1991;146(5):1255-9. [pmid: 1942274].
205 Ju CC, Swan LK, Merriman A, et al. Urinary incontinence among the elderly people of Singapore. Age Ageing. Jul. 1991;20(4):262-6. [pmid: 1927732].
206 Lagro-Janssen TL, Smits AJ, Van Weel C. Women with urinary incontinence: self-perceived worries and general practitioners' knowledge of problem. Br J Gen Pract. Aug. 1990;40(337):331-4. [pmid: 2121179]. [pmcid: 1371311].
207 Molander U, Milsom I, Ekelund P, et al. An epidemiological study of urinary incontinence and related urogenital symptoms in elderly women. Maturitas. Apr. 1990;12(1):51-60. [pmid: 2333037].
208 Uustal Fornell E, Wingren G, Kjolhede P. Factors associated with pelvic floor dysfunction with emphasis on urinary and fecal incontinence and genital prolapse: an epidemiological study. Acta Obstet Gynecol Scand. Apr. 2004;83(4):383-9. [pmid: 15005787].
209 Pescatori M, Mattana C. Factors affecting anal continence after restorative proctocolectomy. Int J Colorectal Dis. Dec. 1990;5(4):213-8. [pmid: 2286805].
210 Belmonte-Montes C, Hagerman G, Vega-Yepez PA, et al. Anal sphincter injury after vaginal delivery in primiparous females. Dis Colon Rectum. Sep. 2001;44(9):1244-8. [pmid: 11584193].
211 Ho YH, Goh HS. The neurophysiological significance of perineal descent. Int J Colorectal Dis. 1995;10(2):107-11. [pmid: 7636369].
212 O'Keefe EA, Talley NJ, Zinsmeister AR, et al. Bowel disorders impair functional status and quality of life in the elderly: a population-based study. J Gerontol A Biol Sci Med Sci. Jul. 1995;50(4):M184-9. [pmid: 7614239].
213 Hinds JP, Eidelman BH, Wald A. Prevalence of bowel dysfunction in multiple sclerosis. A population survey. Gastroenterology. Jun. 1990;98(6):1538-42. [pmid: 2338192].
214 Talley NJ, O'Keefe EA, Zinsmeister AR, et al. Prevalence of gastrointestinal symptoms in the elderly: a population-based study. Gastroenterology. Mar. 1992;102(3):895-901. [pmid: 1537525].
215 Hojberg KE, Salvig JD, Winslow NA, et al. Flatus and faecal incontinence: prevalence and risk factors at 16 weeks of gestation. Bjog. Sep. 2000;107(9):1097-103. [pmid: 11002952].
216 Faltin DL, Sangalli MR, Roche B, et al. Does a second delivery increase the risk of anal incontinence?. Bjog. Jul. 2001;108(7):684-8. [pmid: 11467691].
217 Kirk PM, King RB, Temple R, et al. Long-term follow-up of bowel management after spinal cord injury. SCI Nurs. Jun. 1997;14(2):56-63. [pmid: 9295753].
218 Curless R, French J, Williams GV, et al. Comparison of gastrointestinal symptoms in colorectal carcinoma patients and community controls with respect to age. Gut. Sep. 1994;35(9):1267-70. [pmid: 7959235]. [pmcid: 1375705].
219 Enck P, Bielefeldt K, Rathmann W, et al. Epidemiology of faecal incontinence in selected patient groups. Int J Colorectal Dis. Aug. 1991;6(3):143-6. [pmid: 1744485].
220 Franssen EH, Souren LE, Torossian CL, et al. Utility of developmental reflexes in the differential diagnosis and prognosis of incontinence in Alzheimer's disease. J Geriatr Psychiatry Neurol. Jan. 1997;10(1):22-8. [pmid: 9100155].
221 Fine KD, Meyer RL, Lee EL. The prevalence and causes of chronic diarrhea in patients with celiac sprue treated with a gluten-free diet. Gastroenterology. Jun. 1997;112(6):1830-8. [pmid: 9178673].
222 Oberwalder M, Dinnewitzer A, Baig MK, et al. Do internal anal sphincter defects decrease the success rate of anal sphincter repair?. Tech Coloproctol. Jul. 2006;10(2):94-7. discussion 7. [pmid: 16773293].
223 Rose J, Schneider C, Scheidbach H, et al. Laparoscopic treatment of rectal prolapse: experience gained in a prospective multicenter study. Langenbecks Arch Surg. Jul. 2002;387(34):130-7. [pmid: 12172857].
224 Campbell H, Crawford V, Stout RW. The impact of private residential and nursing care on statutory residential and hospital care of elderly people in south Belfast. Age Ageing. Sep. 1990;19(5):318-24. [pmid: 2251965].
225 Klotz R, Joseph PA, Ravaud JF, et al. The Tetrafigap Survey on the long-term outcome of tetraplegic spinal cord injured persons: Part III. Medical complications and associated factors. Spinal Cord. Sep. 2002;40(9):457-67. [pmid: 12185607].
226 Marcello PW, Roberts PL, Schoetz DJ Jr, et al. Long-term results of the ileoanal pouch procedure. Arch Surg. May. 1993;128(5):500-3. discussion 3–4. [pmid: 8489382].
227 Giordano P, Renzi A, Efron J, et al. Previous sphincter repair does not affect the outcome of repeat repair. Dis Colon Rectum. May. 2002;45(5):635-40. [pmid: 12004213].
228 Mazouni C, Bretelle F, Battar S, et al. Frequency of persistent anal symptoms after first instrumental delivery. Dis Colon Rectum. Jul. 2005;48(7):1432-6. [pmid: 15933796].
229 Guenin MO, Rosenthal R, Kern B, et al. Ferguson hemorrhoidectomy: long-term results and patient satisfaction after Ferguson's hemorrhoidectomy. Dis Colon Rectum. Aug. 2005;48(8):1523-7. [pmid: 15937612].
230 Tocchi A, Mazzoni G, Miccini M, et al. Total lateral sphincterotomy for anal fissure. Int J Colorectal Dis. May. 2004;19(3):245-9. [pmid: 13680282].
231 Wagenius J, Laurin J. Clinical symptoms after anal sphincter rupture: a retrospective study. Acta Obstet Gynecol Scand. Mar. 2003;82(3):246-50. [pmid: 12694121].
232 Quander CR, Morris MC, Melson J, et al. Prevalence of and factors associated with fecal incontinence in a large community study of older individuals. Am J Gastroenterol. Apr. 2005;100(4):905-9. [pmid: 15784039].
233 Schweitzer KJ, Vierhout ME, Milani AL. Surgery for pelvic organ prolapse in women of 80 years of age and older. Acta Obstet Gynecol Scand. Mar. 2005;84(3):286-9. [pmid: 15715538].
234 Sangalli MR, Floris L, Faltin D, et al. Anal incontinence in women with third or fourth degree perineal tears and subsequent vaginal deliveries. Aust N Z J Obstet Gynaecol. Aug. 2000;40(3):244-8. [pmid: 11065029].
235 Siproudhis L, El Abkari M, El Alaoui M, et al. Low rectal volumes in patients suffering from fecal incontinence: what does it mean?. Aliment Pharmacol Ther. Nov 15. 2005;22(10):989-96. [pmid: 16268974].
236 Buchanan RJ, Wang S, Huang C, et al. Analyses of nursing home residents with Parkinson's disease using the minimum data set. Parkinsonism Relat Disord. Jun. 2002;8(5):369-80. [pmid: 15177067].
237 Stenzelius K, Westergren A, Hallberg IR. Bowel function among people 75+ reporting faecal incontinence in relation to help seeking, dependency and quality of life. J Clin Nurs. Mar. 2007;16(3):458-68. [pmid: 17335521].
238 Sullivan SN, Wong C. Runners' diarrhea. Different patterns and associated factors. J Clin Gastroenterol. Mar. 1992;14(2):101-4. [pmid: 1556421].
239 Otegbayo JA, Talabi OA, Akere A, et al. Gastrointestinal complications in stroke survivors. Trop Gastroenterol. Jul–Sep. 2006;27(3):127-30. [pmid: 17310556].
240 Ween JE, Alexander MP, D'Esposito M, et al. Incontinence after stroke in a rehabilitation setting: outcome associations and predictive factors. Neurology. Sep. 1996;47(3):659-63. [pmid: 8797460].
241 Bharucha AE, Zinsmeister AR, Locke GR, et al. Prevalence and burden of fecal incontinence: a population-based study in women. Gastroenterology. Jul. 2005;129(1):42-9. [pmid: 16012933].
242 Johannsson HO, Graf W, Pahlman L. Long-term results of haemorrhoidectomy. Eur J Surg. 2002;168(89):485-9. [pmid: 12549690].
243 Karasick S, Spettell CM. The role of parity and hysterectomy on the development of pelvic floor abnormalities revealed by defecography. AJR Am J Roentgenol. Dec. 1997;169(6):1555-8. [pmid: 9393164].
244 Cavaliere F, Pemberton JH, Cosimelli M, et al. Coloanal anastomosis for rectal cancer. Long-term results at the Mayo and Cleveland Clinics. Dis Colon Rectum. Aug. 1995;38(8):807-12. [pmid: 7634975].
245 Peet SM, Castleden CM, McGrother CW. Prevalence of urinary and faecal incontinence in hospitals and residential and nursing homes for older people. Bmj. Oct 21. 1995;311(7012):1063-4. [pmid: 7580664]. [pmcid: 2551367].
246 Fialkow MF, Melville JL, Lentz GM, et al. The functional and psychosocial impact of fecal incontinence on women with urinary incontinence. Am J Obstet Gynecol. Jul. 2003;189(1):127-9. [pmid: 12861150].
247 Bek KM, Laurberg S. Risks of anal incontinence from subsequent vaginal delivery after a complete obstetric anal sphincter tear. Br J Obstet Gynaecol. Sep. 1992;99(9):724-6. [pmid: 1420009].
248 Goode PS, Burgio KL, Halli AD, et al. Prevalence and correlates of fecal incontinence in community-dwelling older adults. J Am Geriatr Soc. Apr. 2005;53(4):629-35. [pmid: 15817009].
249 Bergmark K, Avall-Lundqvist E, Dickman PW, et al. Patient-rating of distressful symptoms after treatment for early cervical cancer. Acta Obstet Gynecol Scand. May. 2002;81(5):443-50. [pmid: 12027819].
250 Guren MG, Eriksen MT, Wiig JN, et al. Quality of life and functional outcome following anterior or abdominoperineal resection for rectal cancer. Eur J Surg Oncol. Sep. 2005;31(7):735-42. [pmid: 16180267].
251 Gunther K, Braunrieder G, Bittorf BR, et al. Patients with familial adenomatous polyposis experience better bowel function and quality of life after ileorectal anastomosis than after ileoanal pouch. Colorectal Dis. Jan. 2003;5(1):38-44. [pmid: 12780925].
252 Adolfsson J, Helgason AR, Dickman P, et al. Urinary and bowel symptoms in men with and without prostate cancer: results from an observational study in the Stockholm area. Eur Urol. 1998;33(1):11-6.
253 Ellerkmann RM, Cundiff GW, Melick CF, et al. Correlation of symptoms with location and severity of pelvic organ prolapse. Am J Obstet Gynecol. Dec. 2001;185(6):1332-7. discussion 7–8. [pmid: 11744905].
254 Garcia-Aguilar J, Belmonte C, Wong WD, et al. Open vs. closed sphincterotomy for chronic anal fissure: long-term results. Dis Colon Rectum. Apr. 1996;39(4):440-3. [pmid: 8878506].
255 Amdur RJ, Parsons JT, Fitzgerald LT, et al. Adenocarcinoma of the prostate treated with external-beam radiation therapy: 5-year minimum follow-up. Radiother Oncol. Jul. 1990;18(3):235-46. [pmid: 2120741].
256 Sobhgol SS, Alizadeli Charndabee SM. Rate and related factors of dyspareunia in reproductive age women: a cross-sectional study. Int J Impot Res. Jan–Feb. 2007;19(1):88-94. [pmid: 16791280].
257 Drossman DA, Li Z, Andruzzi E, et al. U.S. householder survey of functional gastrointestinal disorders. Prevalence, sociodemography, and health impact. Dig Dis Sci. Sep. 1993;38(9):1569-80. [pmid: 8359066].
258 Nicholls RJ. Restorative proctocolectomy with ileal reservoir: indications and results. Schweiz Med Wochenschr. Apr 7. 1990;120(14):485-8. [pmid: 2159658].
259 Crook J, Esche B, Futter N. Effect of pelvic radiotherapy for prostate cancer on bowel, bladder, and sexual function: the patient's perspective. Urology. Mar. 1996;47(3):387-94. [pmid: 8633407].
260 Schwartz K, Bunner S, Bearer R, et al. Complications from treatment for prostate carcinoma among men in the Detroit area. Cancer. Jul 1. 2002;95(1):82-9. [pmid: 12115320].
261 Gurbuz A, Karateke A, Kabaca C. Enuresis in childhood, and urinary and fecal incontinence in adult life: do they share a common cause?. BJU Int. May. 2005;95(7):1058-62. [pmid: 15839932].
262 Hahnloser D, Pemberton JH, Wolff BG, et al. The effect of ageing on function and quality of life in ileal pouch patients: a single cohort experience of 409 patients with chronic ulcerative colitis. Ann Surg. Oct. 2004;240(4):615-21. discussion 21–3. [pmid: 15383789]. [pmcid: 1356463].
263 Dayton MT, Larsen KR. Should older patients undergo ileal pouch-anal anastomosis?. Am J Surg. Nov. 1996;172(5):444-7. discussion 7–8. [pmid: 8942541].
264 Cukier JM, Cortina-Borja M, Brading AF. A case-control study to examine any association between idiopathic detrusor instability and gastrointestinal tract disorder, and between irritable bowel syndrome and urinary tract disorder. Br J Urol. Jun. 1997;79(6):865-78. [pmid: 9202551].
265 Lovatsis D, Drutz HP. Safety and efficacy of sacrospinous vault suspension. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):308-13. [pmid: 12355291].
266 Menter R, Weitzenkamp D, Cooper D, et al. Bowel management outcomes in individuals with long-term spinal cord injuries. Spinal Cord. Sep. 1997;35(9):608-12. [pmid: 9300968].
267 Gupta PJ. Radiofrequency ablation and plication: a non-resectional therapy for advanced hemorrhoids. J Surg Res. Jun 1. 2005;126(1):66-72. [pmid: 15916977].
268 Malone PS, Wheeler RA, Williams JE. Continence in patients with spina bifida: long term results. Arch Dis Child. Feb. 1994;70(2):107-10. [pmid: 8129429]. [pmcid: 1029710].
269 Helgason AR, Adolfsson J, Dickman P, et al. Waning sexual function—the most important disease-specific distress for patients with prostate cancer. Br J Cancer. Jun. 1996;73(11):1417-21. [pmid: 8645589].
270 Buchanan RJ, Wang S, Ju H. Analyses of the minimum data set: comparisons of nursing home residents with multiple sclerosis to other nursing home residents. Mult Scler. Dec. 2002;8(6):512-22. [pmid: 12474994].
271 Zorzon M, Zivadinov R, Bosco A, et al. Sexual dysfunction in multiple sclerosis: a case-control study. I. Frequency and comparison of groups. Mult Scler. Dec. 1999;5(6):418-27. [pmid: 10618699].
272 Nelson R, Norton N, Cautley E, et al. Community-based prevalence of anal incontinence. Jama. Aug 16. 1995;274(7):559-61. [pmid: 7629985].
273 Giebel GD, Lefering R, Troidl H, et al. Prevalence of fecal incontinence: what can be expected?. Int J Colorectal Dis. 1998;13(2):73-7. [pmid: 9638491].
274 Brandeis GH, Ooi WL, Hossain M, et al. A longitudinal study of risk factors associated with the formation of pressure ulcers in nursing homes. J Am Geriatr Soc. Apr. 1994;42(4):388-93. [pmid: 8144823].
275 Longstreth GF. Bowel patterns and anxiety. Demographic factors. J Clin Gastroenterol. Sep. 1993;17(2):128-32. [pmid: 8409315].
276 Khullar V, Damiano R, Toozs-Hobson P, et al. Prevalence of faecal incontinence among women with urinary incontinence. Br J Obstet Gynaecol. Nov. 1998;105(11):1211-3. [pmid: 9853773].
277 Edwards NI, Jones D. The prevalence of faecal incontinence in older people living at home. Age Ageing. Nov. 2001;30(6):503-7. [pmid: 11742780].
278 Lynch AC, Dobbs BR, Keating J, et al. The prevalence of faecal incontinence and constipation in a general New Zealand population; a postal survey. N Z Med J. Oct 26. 2001;114(1142):474-7. [pmid: 11760243].
279 Perry S, Shaw C, McGrother C, et al. Prevalence of faecal incontinence in adults aged 40 years or more living in the community. Gut. Apr. 2002;50(4):480-4. [pmid: 11889066]. [pmcid: 1773171].
280 Okonkwo JE, Obionu CN, Okonkwo CV, et al. Anal incontinence among Igbo (Nigerian) women. Int J Clin Pract. Apr. 2002;56(3):178-80. [pmid: 12018821].
281 Henningsohn L, Wijkstrom H, Dickman PW, et al. Distressful symptoms after radical radiotherapy for urinary bladder cancer. Radiother Oncol. Feb. 2002;62(2):215-25. [pmid: 11937249].
282 Sakakibara R, Shinotoh H, Uchiyama T, et al. Questionnaire-based assessment of pelvic organ dysfunction in Parkinson's disease. Auton Neurosci. Sep 17. 2001;92(12):76-85. [pmid: 11570707].
283 Eason E, Labrecque M, Marcoux S, et al. Anal incontinence after childbirth. Cmaj. Feb 5. 2002;166(3):326-30. [pmid: 11868640]. [pmcid: 99311].
284 Chen GD, Hu SW, Chen YC, et al. Prevalence and correlations of anal incontinence and constipation in Taiwanese women. Neurourol Urodyn. 2003;22(7):664-9. [pmid: 14595611].
285 Goldberg RP, Kwon C, Gandhi S, et al. Prevalence of anal incontinence among mothers of multiples and analysis of risk factors. Am J Obstet Gynecol. Dec. 2003;189(6):1627-30. discussion 30–1. [pmid: 14710087].
286 Chiarelli P, Murphy B, Cockburn J. Fecal incontinence after high-risk delivery. Obstet Gynecol. Dec. 2003;102(6):1299-305. [pmid: 14662218].
287 Fenner DE, Genberg B, Brahma P, et al. Fecal and urinary incontinence after vaginal delivery with anal sphincter disruption in an obstetrics unit in the United States. Am J Obstet Gynecol. Dec. 2003;189(6):1543-9. discussion 9–50. [pmid: 14710059].
288 Korman HJ, Mulholland TL, Huang R. Preservation of fecal continence and bowel function after radical perineal and retropubic prostatectomy: a questionnaire-based outcomes study. Prostate Cancer Prostatic Dis. 2004;7(3):249-52. [pmid: 15249929].
289 Delaney CP, Fazio VW, Remzi FH, et al. Prospective, age-related analysis of surgical results, functional outcome, and quality of life after ileal pouch-anal anastomosis. Ann Surg. Aug. 2003;238(2):221-8. [pmid: 12894015]. [pmcid: 1422678].
290 Lunniss PJ, Gladman MA, Hetzer FH, et al. Risk factors in acquired faecal incontinence. J R Soc Med. Mar. 2004;97(3):111-6. [pmid: 14996955]. [pmcid: 1079318].
291 Thomas VS. Excess functional disability among demented subjects? Findings from the Canadian Study of Health and Aging. Dement Geriatr Cogn Disord. May–Jun. 2001;12(3):206-10. [pmid: 11244214].
292 MacArthur C, Bick DE, Keighley MR. Faecal incontinence after childbirth. Br J Obstet Gynaecol. Jan. 1997;104(1):46-50. [pmid: 8988696].
293 Buchanan RJ, Choi M, Wang S, et al. Analyses of nursing home residents in hospice care using the minimum data set. Palliat Med. Nov. 2002;16(6):465-80. [pmid: 12465693].
294 Buchanan RJ, Wang S, Huang C, et al. Profiles of nursing home residents with multiple sclerosis using the minimum data set. Mult Scler. Jun. 2001;7(3):189-200. [pmid: 11475444].
295 Chiang L, Ouslander J, Schnelle J, et al. Dually incontinent nursing home residents: clinical characteristics and treatment differences. J Am Geriatr Soc. Jun. 2000;48(6):673-6. [pmid: 10855605].
296 Chia YW, Fowler CJ, Kamm MA, et al. Prevalence of bowel dysfunction in patients with multiple sclerosis and bladder dysfunction. J Neurol. Jan. 1995;242(2):105-8. [pmid: 7707085].
297 Abramowitz L, Sobhani I, Ganansia R, et al. Are sphincter defects the cause of anal incontinence after vaginal delivery? Results of a prospective study. Dis Colon Rectum. May. 2000;43(5):590-6. discussion 6–8. [pmid: 10826416].
298 Zetterstrom JP, Lopez A, Anzen B, et al. Anal incontinence after vaginal delivery: a prospective study in primiparous women. Br J Obstet Gynaecol. Apr. 1999;106(4):324-30. [pmid: 10426238].
299 Galandiuk S, Pemberton JH, Tsao J, et al. Delayed ileal pouch-anal anastomosis. Complications and functional results. Dis Colon Rectum. Sep. 1991;34(9):755-8. [pmid: 1914739].
300 Nelson R, Furner S, Jesudason V. Urinary incontinence in Wisconsin skilled nursing facilities: prevalence and associations in common with fecal incontinence. J Aging Health. Nov. 2001;13(4):539-47. [pmid: 11813740].
301 Borrie MJ, Davidson HA. Incontinence in institutions: costs and contributing factors. Cmaj. Aug 1. 1992;147(3):322-8. [pmid: 1643598]. [pmcid: 1336202].
302 Mecocci P, von Strauss E, Cherubini A, et al. Cognitive impairment is the major risk factor for development of geriatric syndromes during hospitalization: results from the GIFA study. Dement Geriatr Cogn Disord. 2005;20(4):262-9. [pmid: 16103670].
303 Jackson SL, Weber AM, Hull TL, et al. Fecal incontinence in women with urinary incontinence and pelvic organ prolapse. Obstet Gynecol. Mar. 1997;89(3):423-7. [pmid: 9052598].
304 Endo JO, Chen S, Potter JF, et al. Vitamin B(12) deficiency and incontinence: is there an association?. J Gerontol A Biol Sci Med Sci. Sep. 2002;57(9):M583-7. [pmid: 12196495].
305 Chassagne P, Landrin I, Neveu C, et al. Fecal incontinence in the institutionalized elderly: incidence, risk factors, and prognosis. Am J Med. Feb. 1999;106(2):185-90. [pmid: 10230748].
306 Nelson R, Furner S, Jesudason V. Fecal incontinence in Wisconsin nursing homes: prevalence and associations. Dis Colon Rectum. Oct. 1998;41(10):1226-9. [pmid: 9788384].
307 De Leeuw JW, Vierhout ME, Struijk PC, et al. Anal sphincter damage after vaginal delivery: functional outcome and risk factors for fecal incontinence. Acta Obstet Gynecol Scand. Sep. 2001;80(9):830-4. [pmid: 11531634].
308 Bliss DZ, Fischer LR, Savik K, et al. Severity of fecal incontinence in community-living elderly in a health maintenance organization. Res Nurs Health. Jun. 2004;27(3):162-73. [pmid: 15141369].
309 O'Brien J, Austin M, Sethi P, et al. Urinary incontinence: prevalence, need for treatment, and effectiveness of intervention by nurse. BMJ. Nov 23. 1991;303(6813):1308-12. [pmid: 1747675]. [pmcid: 1671402].
310 Temml C, Heidler S, Ponholzer A, et al. Prevalence of the overactive bladder syndrome by applying the International Continence Society definition. Eur Urol. Oct. 2005;48(4):622-7. [pmid: 15964133].
311 Roberts RO, Jacobsen SJ, Jacobson DJ, et al. Natural history of prostatism: high American Urological Association Symptom scores among community-dwelling men and women with urinary incontinence. Urology. Feb. 1998;51(2):213-9. [pmid: 9495700].
312 Perry S, Shaw C, Assassa P, et al. An epidemiological study to establish the prevalence of urinary symptoms and felt need in the community: the Leicestershire MRC Incontinence Study. Leicestershire MRC Incontinence Study Team. J Public Health Med. Sep. 2000;22(3):427-34. [pmid: 11077920].
313 Goluboff ET, Saidi JA, Mazer S, et al. Urinary continence after radical prostatectomy: the Columbia experience. J Urol. Apr. 1998;159(4):1276-80. [pmid: 9507852].
314 Diokno AC, Brock BM, Herzog AR, et al. Medical correlates of urinary incontinence in the elderly. Urology. Aug. 1990;36(2):129-38. [pmid: 2385880].
315 Haltbakk J, Hanestad BR, Hunskaar S. Relevance and variability of the severity of incontinence, and increased daytime and night-time voiding frequency, associated with quality of life in men with lower urinary tract symptoms. BJU Int. Jul. 2005;96(1):83-7. [pmid: 15963126].
316 Joly F, Brune D, Couette JE, et al. Health-related quality of life and sequelae in patients treated with brachytherapy and external beam irradiation for localized prostate cancer. Ann Oncol. Jul. 1998;9(7):751-7. [pmid: 9739442].
317 Diokno AC, Brown MB, Herzog AR. Relationship between use of diuretics and continence status in the elderly. Urology. Jul. 1991;38(1):39-42. [pmid: 1866856].
318 Ouslander JG, Zarit SH, Orr NK, et al. Incontinence among elderly community-dwelling dementia patients. Characteristics, management, and impact on caregivers. J Am Geriatr Soc. Apr. 1990;38(4):440-5. [pmid: 2329252].
319 Diokno AC, Brown MB, Herzog AR. Sexual function in the elderly. Arch Intern Med. Jan. 1990;150(1):197-200. [pmid: 2297288].
320 Muller N. What Americans understand and how they are affected by bladder control problems: highlights of recent nationwide consumer research. Urol Nurs. Apr. 2005;25(2):109-15. [pmid: 15900979].
321 Goepel M, Hoffmann JA, Piro M, et al. Prevalence and physician awareness of symptoms of urinary bladder dysfunction. Eur Urol. Mar. 2002;41(3):234-9. [pmid: 12180221].
322 Lee E, Yoo KY, Kim Y, et al. Prevalence of lower urinary tract symptoms in Korean men in a community-based study. Eur Urol. 1998;33(1):17-21. [pmid: 9471036].
323 Sladden MJ, Hughes AM, Hirst GH, et al. A community study of lower urinary tract symptoms in older men in Sydney, Australia. Aust N Z J Surg. May. 2000;70(5):322-8. [pmid: 10830592].
324 Brocklehurst J, Dickinson E, Windsor J. Laxatives and faecal incontinence in long-term care. Elder Care. Aug–Sep. 1998;10(4):22-5. [pmid: 9855925].
325 Haas U, Geng V, Evers GC, et al. Bowel management in patients with spinal cord injury — a multicentre study of the German speaking society of paraplegia (DMGP). Spinal Cord. Dec. 2005;43(12):724-30. [pmid: 16010276].
326 Chaliha C, Kalia V, Stanton SL, et al. Antenatal prediction of postpartum urinary and fecal incontinence. Obstet Gynecol. Nov. 1999;94(5 Pt 1):689-94. [pmid: 10546711].
327 Alnaif B, Drutz HP. The prevalence of urinary and fecal incontinence in Canadian secondary school teenage girls: questionnaire study and review of the literature. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):134-7. discussion8. [pmid: 11374512].
328 Faltin DL, Sangalli MR, Curtin F, et al. Prevalence of anal incontinence and other anorectal symptoms in women. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):117-20. discussion 21. [pmid: 11374509].
329 Hojberg KE, Hundborg HH, Ryhammer AM, et al. The impact of delivery on anorectal function in women with and women without anal incontinence—a prospective study. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):38-45. discussion. [pmid: 12601515].
330 Walter S, Hallbook O, Gotthard R, et al. A population-based study on bowel habits in a Swedish community: prevalence of faecal incontinence and constipation. Scand J Gastroenterol. Aug. 2002;37(8):911-6. [pmid: 12229965].
331 Boreham MK, Richter HE, Kenton KS, et al. Anal incontinence in women presenting for gynecologic care: prevalence, risk factors, and impact upon quality of life. Am J Obstet Gynecol. May. 2005;192(5):1637-42. [pmid: 15902170].
332 Ballester A, Minguez M, Herreros B, et al. Prevalence of silent fecal and urinary incontinence in women from the town of Teruel. Rev Esp Enferm Dig. Feb. 2005;97(2):78-86. [pmid: 15801883].
333 Gordon D, Groutz A, Goldman G, et al. Anal incontinence: prevalence among female patients attending a urogynecologic clinic. Neurourol Urodyn. 1999;18(3):199-204. [pmid: 10338440].
334 Roche B, Chautems R, Rakotoarimanana R, et al. [Epidemiology of anal incontinence]. Rev Med Suisse Romande. Feb. 2002;122(2):71-4. [pmid: 11977466].
335 Lam K, Chen, Lubowski. Talley Prevalence of faecal incontinence: obstetric and constipation-related risk factors; a population-based study. Colorectal Disease. 1999;1(4):197-203.
336 Kjolhede P, Hallbook O, Ryden G, et al. Anorectal manometry in women with urinary stress incontinence. Acta Obstet Gynecol Scand. Mar. 1997;76(3):266-70. [pmid: 9093143].
337 Lopes MC, Teixeira MG, Jacob Filho W, et al. [Prevalence of anal incontinence in the elderly population: an epidemiological study of the elderly population served at the geriatric ambulatory service of the Hospital das Clinicas da Faculdade de Medicina da Universidade de Sao Paulo]. Rev Hosp Clin Fac Med Sao Paulo. Jan–Feb. 1997;52(1):1-12. [pmid: 9334464].
338 Melville JL, Fan MY, Newton K, et al. Fecal incontinence in US women: a population-based study. Am J Obstet Gynecol. Dec. 2005;193(6):2071-6. [pmid: 16325618].
339 Kalantar JS, Howell S, Talley NJ. Prevalence of faecal incontinence and associated risk factors; an underdiagnosed problem in the Australian community?. Med J Aust. Jan 21. 2002;176(2):54-7. [pmid: 11936284].
340 Roberts RO, Jacobsen SJ, Reilly WT, et al. Prevalence of combined fecal and urinary incontinence: a community-based study. J Am Geriatr Soc. Jul. 1999;47(7):837-41. [pmid: 10404928].
341 Thomas TM, Egan M, Walgrove A, et al. The prevalence of faecal and double incontinence. Community Med. Aug. 1984;6(3):216-20. [pmid: 6478780].
342 Verhagen TE, Lagro-Janssen AL. [Fecal incontinence in community-dwelling elderly: findings from a study of prevalence, consultation of physicians, psychosocial aspects and treatment]. Ned Tijdschr Geneeskd. Apr 14. 2001;145(15):741-4. [pmid: 11332258].
343 Wetle T, Scherr P, Branch LG, et al. Difficulty with holding urine among older persons in a geographically defined community: prevalence and correlates. J Am Geriatr Soc. Apr. 1995;43(4):349-55. [pmid: 7706622].
344 Rizk DE, Hassan MY, Shaheen H, et al. The prevalence and determinants of health care-seeking behavior for fecal incontinence in multiparous United Arab Emirates females. Dis Colon Rectum. Dec. 2001;44(12):1850-6. [pmid: 11742174].
345 Manning J, Eyers AA, Korda A, et al. Is there an association between fecal incontinence and lower urinary dysfunction?. Dis Colon Rectum. Jun. 2001;44(6):790-8. [pmid: 11391137].
346 Mann CH, Radley SC, Begum G, et al. Constipation, faecal incontinence and urinary symptoms in women awaiting hysterectomy. J Obstet Gynaecol. Sep. 2000;20(5):530-2. [pmid: 15512644].
347 Soligo MS, S, Teruzzi CM, Lalia M, Citterio S, Milani R. Role of the General Practitioner in Detecting Urinary and Bowel Symptoms. Prevalence and Rate of Spontaneous Reporting. GASTROENTEROLOGY INTERNATIONAL. 2000;13(4):172-3.
348 Brittain K, Perry S, Shaw C, et al. Isolated urinary, fecal, and double incontinence: Prevalence and degree of soiling in stroke survivors. J Am Geriatr Soc. Dec. 2006;54(12):1915-9. [pmid: 17198499].
349 Damon H, Guye O, Seigneurin A, et al. Prevalence of anal incontinence in adults and impact on quality-of-life. Gastroenterol Clin Biol. Jan. 2006;30(1):37-43. [pmid: 16514381].
350 Johanson JF, Lafferty J. Epidemiology of fecal incontinence: the silent affliction. Am J Gastroenterol. Jan. 1996;91(1):33-6. [pmid: 8561140].
351 Bytzer P, Talley NJ, Leemon M, et al. Prevalence of gastrointestinal symptoms associated with diabetes mellitus: a population-based survey of 15,000 adults. Arch Intern Med. Sep 10. 2001;161(16):1989-96. [pmid: 11525701].
352 Campbell AJ, Reinken J, McCosh L. Incontinence in the elderly: prevalence and prognosis. Age Ageing. Mar. 1985;14(2):65-70. [pmid: 4003185].
353 Brown JS, Grady D, Ouslander JG, et al. Prevalence of urinary incontinence and associated risk factors in postmenopausal women. Heart & Estrogen/Progestin Replacement Study (HERS) Research Group. Obstet Gynecol. Jul. 1999;94(1):66-70. [pmid: 10389720].
354 Moller LA, Lose G, Jorgensen T. The prevalence and bothersomeness of lower urinary tract symptoms in women 40–60 years of age. Acta Obstet Gynecol Scand. Apr. 2000;79(4):298-305. [pmid: 10746846].
355 Holtedahl K, Hunskaar S. Prevalence, 1-year incidence and factors associated with urinary incontinence: a population based study of women 50–74 years of age in primary care. Maturitas. Jan 12. 1998;28(3):205-11. [pmid: 9571595].
356 Hvidman L, Foldspang A, Mommsen S, et al. Menstrual cycle, female hormone use and urinary incontinence in premenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):56-61. discussion. [pmid: 12601518].
357 Fultz NH, Herzog AR, Raghunathan TE, et al. Prevalence and severity of urinary incontinence in older African American and Caucasian women. J Gerontol A Biol Sci Med Sci. Jun. 1999;54(6):M299-303. [pmid: 10411017].
358 Persson J, Wolner-Hanssen P, Rydhstroem H. Obstetric risk factors for stress urinary incontinence: a population-based study. Obstet Gynecol. Sep. 2000;96(3):440-5. [pmid: 10960639].
359 Moghaddas F, Lidfeldt J, Nerbrand C, et al. Prevalence of urinary incontinence in relation to self-reported depression, intake of serotonergic antidepressants, and hormone therapy in middle-aged women: a report from the Women's Health in the Lund Area study. Menopause. May–Jun. 2005;12(3):318-24. [pmid: 15879921].
360 Teleman PM, Lidfeldt J, Nerbrand C, et al. Overactive bladder: prevalence, risk factors and relation to stress incontinence in middle-aged women. Bjog. Jun. 2004;111(6):600-4. [pmid: 15198789].
361 Hannestad YS, Rortveit G, Daltveit AK, et al. Are smoking and other lifestyle factors associated with female urinary incontinence? The Norwegian EPINCONT Study. Bjog. Mar. 2003;110(3):247-54. [pmid: 12628262].
362 Burgio KL, Locher JL, Zyczynski H, et al. Urinary incontinence during pregnancy in a racially mixed sample: characteristics and predisposing factors. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):69-73. [pmid: 8798089].
363 Wilson PD, Herbison RM, Herbison GP. Obstetric practice and the prevalence of urinary incontinence three months after delivery. Br J Obstet Gynaecol. Feb. 1996;103(2):154-61. [pmid: 8616133].
364 Farrell SA, Allen VM, Baskett TF. Parturition and urinary incontinence in primiparas. Obstet Gynecol. Mar. 2001;97(3):350-6. [pmid: 11239635].
365 Eliasson K, Nordlander I, Larson B, et al. Influence of physical activity on urinary leakage in primiparous women. Scand J Med Sci Sports. Apr. 2005;15(2):87-94. [pmid: 15773862].
366 Burgio KL, Borello-France D, Richter HE, et al. Risk Factors for Fecal and Urinary Incontinence After Childbirth: The Childbirth and Pelvic Symptoms Study. Am J Gastroenterol 2007 Jun 15.
367 Casey BM, Schaffer JI, Bloom SL, et al. Obstetric antecedents for postpartum pelvic floor dysfunction. Am J Obstet Gynecol. May. 2005;192(5):1655-62. [pmid: 15902173].
368 Kocak I, Okyay P, Dundar M, et al. Female urinary incontinence in the west of Turkey: prevalence, risk factors and impact on quality of life. Eur Urol. Oct. 2005;48(4):634-41. [pmid: 15963633].
369 Van Kampen M, De Weerdt W, Van Poppel H, et al. Urinary incontinence following transurethral, transvesical and radical prostatectomy. Retrospective study of 489 patients. Acta Urol Belg. Dec. 1997;65(4):1-7.
370 Lee WR, Schultheiss TE, Hanlon AL, et al. Urinary incontinence following external-beam radiotherapy for clinically localized prostate cancer. Urology. Jul. 1996;48(1):95-9. [pmid: 8693660].
371 Augustin H, Pummer K, Daghofer F, et al. Patient self-reporting questionnaire on urological morbidity and bother after radical retropubic prostatectomy. Eur Urol. Aug. 2002;42(2):112-17. [pmid: 12160580].
372 Liu M, Pickles T, Berthelet E, et al. Urinary incontinence in prostate cancer patients treated with external beam radiotherapy. Radiother Oncol. Feb. 2005;74(2):197-201. [pmid: 15818868].
373 Sandhu AS, Zelefsky MJ, Lee HJ, et al. Long-term urinary toxicity after 3-dimensional conformal radiotherapy for prostate cancer in patients with prior history of transurethral resection. Int J Radiat Oncol Biol Phys. Oct 1. 2000;48(3):643-7. [pmid: 11020559].
374 Gray M, Petroni GR, Theodorescu D. Urinary function after radical prostatectomy: a comparison of the retropubic and perineal approaches. Urology. May. 1999;53(5):881-90. discussion 90–1. [pmid: 10223478].
375 Catalona WJ, Carvalhal GF, Mager DE, et al. Potency, continence and complication rates in 1,870 consecutive radical retropubic prostatectomies. J Urol. Aug. 1999;162(2):433-8. [pmid: 10411052].
376 Hisasue S, Takahashi A, Kato R, et al. Early and late complications of radical retropubic prostatectomy: experience in a single institution. Jpn J Clin Oncol. May. 2004;34(5):274-9. [pmid: 15231863].
377 Olsson LE, Salomon L, Nadu A, et al. Prospective patient-reported continence after laparoscopic radical prostatectomy. Urology. Oct. 2001;58(4):570-2. [pmid: 11597541].
378 Fowler FJ Jr, Barry MJ, Lu-Yao G, et al. Outcomes of external-beam radiation therapy for prostate cancer: a study of Medicare beneficiaries in three surveillance, epidemiology, and end results areas. J Clin Oncol. Aug. 1996;14(8):2258-65. [pmid: 8708715].
379 Ramon J, Leandri P, Rossignol G, et al. Urinary continence following radical retropubic prostatectomy. Br J Urol. Jan. 1993;71(1):47-51. [pmid: 8435736].
380 Lowe BA. Comparison of bladder neck preservation to bladder neck resection in maintaining postrostatectomy urinary continence. Urology. Dec. 1996;48(6):889-93. [pmid: 8973672].
381 Weldon VE, Tavel FR, Neuwirth H. Continence, potency and morbidity after radical perineal prostatectomy. J Urol. Oct. 1997;158(4):1470-5. [pmid: 9302145].
382 Bishoff JT, Motley G, Optenberg SA, et al. Incidence of fecal and urinary incontinence following radical perineal and retropubic prostatectomy in a national population. J Urol. Aug. 1998;160(2):454-8. [pmid: 9679897].
383 Horie S, Tobisu KI, Fujimoto H, et al. Urinary incontinence after non-nerve-sparing radical prostatectomy with neoadjuvant androgen deprivation. Urology. Mar. 1999;53(3):561-7. [pmid: 10096385].
384 Benoit RM, Naslund MJ, Cohen JK. Complications after prostate brachytherapy in the Medicare population. Urology. Jan. 2000;55(1):91-6. [pmid: 10654901].
385 Poon M, Ruckle H, Bamshad BR, et al. Radical retropubic prostatectomy: bladder neck preservation versus reconstruction. J Urol. Jan. 2000;163(1):194-8. [pmid: 10604345].
386 Moinzadeh A, Shunaigat AN, Libertino JA. Urinary incontinence after radical retropubic prostatectomy: the outcome of a surgical technique. BJU Int. Sep. 2003;92(4):355-9. [pmid: 12930418].
387 Salomon L, Saint F, Anastasiadis AG, et al. Combined reporting of cancer control and functional results of radical prostatectomy. Eur Urol. Dec. 2003;44(6):656-60. [pmid: 14644116].
388 Deliveliotis C, Protogerou V, Alargof E, et al. Radical prostatectomy: bladder neck preservation and puboprostatic ligament sparing—effects on continence and positive margins. Urology. Nov. 2002;60(5):855-8. [pmid: 12429315].
389 Moore KN, Truong V, Estey E, et al. Urinary Incontinence After Radical Prostatectomy: Can Men at Risk Be Identified Preoperatively?. J Wound Ostomy Continence Nurs. May/June. 2007;34(3):270-9. [pmid: 17505246].
390 Eastham JA, Kattan MW, Rogers E, et al. Risk factors for urinary incontinence after radical prostatectomy. J Urol. Nov. 1996;156(5):1707-13. [pmid: 8863576].
391 Begg CB, Riedel ER, Bach PB, et al. Variations in morbidity after radical prostatectomy. N Engl J Med. Apr 11. 2002;346(15):1138-44. [pmid: 11948274].
392 Stanford JL, Feng Z, Hamilton AS, et al. Urinary and sexual function after radical prostatectomy for clinically localized prostate cancer: the Prostate Cancer Outcomes Study. Jama. Jan 19. 2000;283(3):354-60. [pmid: 10647798].
393 Emberton M, Neal DE, Black N, et al. The effect of prostatectomy on symptom severity and quality of life. Br J Urol. Feb. 1996;77(2):233-47. [pmid: 8800892].
394 Fowler FJ Jr, Barry MJ, Lu-Yao G, et al. Effect of radical prostatectomy for prostate cancer on patient quality of life: results from a Medicare survey. Urology. Jun. 1995;45(6):1007-13. discussion 13–5. [pmid: 7771002].
395 Kundu SD, Roehl KA, Eggener SE, et al. Potency, continence and complications in 3,477 consecutive radical retropubic prostatectomies. J Urol. Dec. 2004;172(6 Pt 1):2227-31. [pmid: 15538237].
396 Harris MJ. Radical perineal prostatectomy: cost efficient, outcome effective, minimally invasive prostate cancer management. Eur Urol. Sep. 2003;44(3):303-8. discussion 8. [pmid: 12932927].
397 Varkarakis J, Wirtenberger W, Pinggera GM, et al. Evaluation of urinary extravasation and results after continence-preserving radical retropubic prostatectomy. BJU Int. Nov. 2004;94(7):991-5. [pmid: 15541115].
398 Lepor H, Kaci L. The impact of open radical retropubic prostatectomy on continence and lower urinary tract symptoms: a prospective assessment using validated self-administered outcome instruments. J Urol. Mar. 2004;171(3):1216-9. [pmid: 14767305].
399 Penson DF, McLerran D, Feng Z, et al. 5-year urinary and sexual outcomes after radical prostatectomy: results from the prostate cancer outcomes study. J Urol. May. 2005;173(5):1701-5. [pmid: 15821561].
400 Sacco E, Prayer-Galetti T, Pinto F, et al. Urinary incontinence after radical prostatectomy: incidence by definition, risk factors and temporal trend in a large series with a long-term follow-up. BJU Int. Jun. 2006;97(6):1234-41. [pmid: 16686718].
401 Saranchuk JW, Kattan MW, Elkin E, et al. Achieving optimal outcomes after radical prostatectomy. J Clin Oncol. Jun 20. 2005;23(18):4146-51. [pmid: 15961762].
402 van Randenborgh H, Paul R, Kubler H, et al. Improved urinary continence after radical retropubic prostatectomy with preparation of a long, partially intraprostatic portion of the membraneous urethra: an analysis of 1013 consecutive cases. Prostate Cancer Prostatic Dis. 2004;7(3):253-7. [pmid: 15184863].
403 Mettlin CJ, Murphy GP, Sylvester J, et al. Results of hospital cancer registry surveys by the American College of Surgeons: outcomes of prostate cancer treatment by radical prostatectomy. Cancer. Nov 1. 1997;80(9):1875-81. [pmid: 9351563].
404 Macarthur C, Glazener C, Lancashire R, et al. Faecal incontinence and mode of first and subsequent delivery: a six-year longitudinal study. Bjog. Aug. 2005;112(8):1075-82. [pmid: 16045521].
405 MacArthur C, Glazener CM, Wilson PD, et al. Obstetric practice and faecal incontinence three months after delivery. Bjog. Jul. 2001;108(7):678-83. [pmid: 11467690].
406 Richter HE, Burgio KL, Clements RH, et al. Urinary and anal incontinence in morbidly obese women considering weight loss surgery. Obstet Gynecol. Dec. 2005;106(6):1272-7. [pmid: 16319252].
407 Nelson RL, Furner SE. Risk factors for the development of fecal and urinary incontinence in Wisconsin nursing home residents. Maturitas. Sep 16. 2005;52(1):26-31. [pmid: 16143223].
408 Ng SC, Chen YC, Lin LY, et al. Anorectal dysfunction in women with urinary incontinence or lower urinary tract symptoms. Int J Gynaecol Obstet. May. 2002;77(2):139-45. [pmid: 12031564].
409 Meschia M, Buonaguidi A, Pifarotti P, et al. Prevalence of anal incontinence in women with symptoms of urinary incontinence and genital prolapse. Obstet Gynecol. Oct. 2002;100(4):719-23. [pmid: 12383540].
410 Guise JM, Morris C, Osterweil P, et al. Incidence of fecal incontinence after childbirth. Obstet Gynecol. Feb. 2007;109(2 Pt 1):281-8. [pmid: 17267825].
411 Kienle P, Abend F, Dueck M, et al. Influence of intraoperative and postoperative radiotherapy on functional outcome in patients undergoing standard and deep anterior resection for rectal cancer. Dis Colon Rectum. May. 2006;49(5):557-67. [pmid: 16550319].
412 Welsh FK, McFall M, Mitchell G, et al. Pre-operative short-course radiotherapy is associated with faecal incontinence after anterior resection. Colorectal Dis. Nov. 2003;5(6):563-8. [pmid: 14617241].
413 Tanum G, Tveit K, Karlsen KO, et al. Chemotherapy and radiation therapy for anal carcinoma. Survival and late morbidity. Cancer. May 15. 1991;67(10):2462-6. [pmid: 2015547].
414 Norderval S, Nsubuga D, Bjelke C, et al. Anal incontinence after obstetric sphincter tears: incidence in a Norwegian county. Acta Obstet Gynecol Scand. Oct. 2004;83(10):989-94. [pmid: 15453900].
415 Harari D, Coshall C, Rudd AG, et al. New-onset fecal incontinence after stroke: prevalence, natural history, risk factors, and impact. Stroke. Jan. 2003;34(1):144-50. [pmid: 12511766].
416 Nakayama H, Jorgensen HS, Pedersen PM, et al. Prevalence and risk factors of incontinence after stroke. The Copenhagen Stroke Study. Stroke. Jan. 1997;28(1):58-62. [pmid: 8996489].
417 Ho YH, Muller R, Veitch C, et al. Faecal incontinence: an unrecognised epidemic in rural North Queensland? Results of a hospital-based outpatient study. Aust J Rural Health. Feb. 2005;13(1):28-34. [pmid: 15720312].
418 Johanson JF, Irizarry F, Doughty A. Risk factors for fecal incontinence in a nursing home population. J Clin Gastroenterol. Apr. 1997;24(3):156-60. [pmid: 9179734].
419 Reissman P, Teoh TA, Weiss EG, et al. Functional outcome of the double stapled ileoanal reservoir in patients more than 60 years of age. Am Surg. Mar. 1996;62(3):178-83. [pmid: 8607574].
420 Lohmuller JL, Pemberton JH, Dozois RR, et al. Pouchitis and extraintestinal manifestations of inflammatory bowel disease after ileal pouch-anal anastomosis. Ann Surg. May. 1990;211(5):622-7. discussion 7–9. [pmid: 2339922]. [pmcid: 1358238].
421 Gonzalez-Argente FX, Jain A, Nogueras JJ, et al. Prevalence and severity of urinary incontinence and pelvic genital prolapse in females with anal incontinence or rectal prolapse. Dis Colon Rectum. Jul. 2001;44(7):920-6. [pmid: 11496068].
422 Bharucha AE, Zinsmeister AR, Locke GR, et al. Risk factors for fecal incontinence: a population-based study in women. Am J Gastroenterol. Jun. 2006;101(6):1305-12. [pmid: 16771954].
423 O'Connell B, Baker L, Munro I. The nature and impact of incontinence in men who have undergone prostate surgery and implications for nursing practice. Contemp Nurse. Feb. 2007;24(1):65-78. [pmid: 17348784].
424 Abramov Y, Sand PK, Botros SM, et al. Risk factors for female anal incontinence: new insight through the Evanston-Northwestern twin sisters study. Obstet Gynecol. Oct. 2005;106(4):726-32. [pmid: 16199628].
425 Weber AM, Walters MD, Ballard LA, et al. Posterior vaginal prolapse and bowel function. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1446-9. discussion 9–50. [pmid: 9855579].
426 Soligo M, Salvatore S, Emmanuel AV, et al. Patterns of constipation in urogynecology: clinical importance and pathophysiologic insights. Am J Obstet Gynecol. Jul. 2006;195(1):50-5. [pmid: 16813743].
427 Leroi AM, Weber J, Menard JF, et al. Prevalence of anal incontinence in 409 patients investigated for stress urinary incontinence. Neurourol Urodyn. 1999;18(6):579-90. [pmid: 10529706].
428 Parmentier H, Damon H, Henry L, et al. Frequency of anal incontinence and results of pelvic viscerography in 291 women with pelvic organ prolapse. Gastroenterol Clin Biol. Mar. 2004;28(3):226-30. [pmid: 15094671].
429 Soligo M, Salvatore S, Milani R, et al. Double incontinence in urogynecologic practice: a new insight. Am J Obstet Gynecol. Aug. 2003;189(2):438-43. [pmid: 14520214].
430 Jelovsek JE, Barber MD, Paraiso MF, et al. Functional bowel and anorectal disorders in patients with pelvic organ prolapse and incontinence. Am J Obstet Gynecol. Dec. 2005;193(6):2105-11. [pmid: 16325624].
431 Kjolhede P, Wahlstrom J, Wingren G. Pelvic floor dysfunction after Burch colposuspension—a comprehensive study. Part II. Acta Obstet Gynecol Scand. Sep. 2005;84(9):902-8. [pmid: 16097984].
432 Nichols CM, Ramakrishnan V, Gill EJ, et al. Anal incontinence in women with and those without pelvic floor disorders. Obstet Gynecol. Dec. 2005;106(6):1266-71. [pmid: 16319251].
433 Groutz A, Fait G, Lessing JB, et al. Incidence and obstetric risk factors of postpartum anal incontinence. Scand J Gastroenterol. Mar. 1999;34(3):315-8. [pmid: 10232879].
434 Bugg GJ, Hosker GL, Kiff ES. Routine symptom screening for postnatal urinary and anal incontinence in new mothers from a district. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):405-8. [pmid: 15891806].
435 Sze EH. Anal incontinence among women with one versus two complete third-degree perineal lacerations. Int J Gynaecol Obstet. Sep. 2005;90(3):213-7. [pmid: 15970289].
436 Sze EH. Prevalence and severity of anal incontinence in women with and without additional vaginal deliveries after a fourth-degree perineal laceration. Dis Colon Rectum. Jan. 2005;48(1):66-9. [pmid: 15690659].
437 Nygaard IE, Rao SS, Dawson JD. Anal incontinence after anal sphincter disruption: a 30-year retrospective cohort study. Obstet Gynecol. Jun. 1997;89(6):896-901. [pmid: 9170461].
438 McKinnie V, Swift SE, Wang W, et al. The effect of pregnancy and mode of delivery on the prevalence of urinary and fecal incontinence. Am J Obstet Gynecol. Aug. 2005;193(2):512-7. discussion 7–8. [pmid: 16098879].
439 Walsh CJ, Mooney EF, Upton GJ, et al. Incidence of third-degree perineal tears in labour and outcome after primary repair. Br J Surg. Feb. 1996;83(2):218-21. [pmid: 8689168].
440 Frudinger A, Halligan S, Spencer JA, et al. Influence of the subpubic arch angle on anal sphincter trauma and anal incontinence following childbirth. Bjog. Nov. 2002;109(11):1207-12. [pmid: 12452456].
441 van Brummen HJ, Bruinse HW, van de Pol G, et al. Defecatory symptoms during and after the first pregnancy: prevalences and associated factors. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):224-30. [pmid: 16077997].
442 Faltin DL, Otero M, Petignat P, et al. Women's health 18 years after rupture of the anal sphincter during childbirth: I. Fecal incontinence. Am J Obstet Gynecol. May. 2006;194(5):1255-9. [pmid: 16647908].
443 Lal M, C HM, Callender R, et al. Does cesarean delivery prevent anal incontinence?. Obstet Gynecol. Feb. 2003;101(2):305-12. [pmid: 12576254].
444 Signorello LB, Harlow BL, Chekos AK, et al. Midline episiotomy and anal incontinence: retrospective cohort study. Bmj. Jan 8. 2000;320(7227):86-90. [pmid: 10625261]. [pmcid: 27253].
445 Sultan AH, Kamm MA, Bartram CI, et al. Anal sphincter trauma during instrumental delivery. Int J Gynaecol Obstet. Dec. 1993;43(3):263-70. [pmid: 7907036].
446 Meyer S, Hohlfeld P, Achtari C, et al. Birth trauma: short and long term effects of forceps delivery compared with spontaneous delivery on various pelvic floor parameters. Bjog. Nov. 2000;107(11):1360-5. [pmid: 11117762].
447 Schraffordt Koops SE, Vervest HA, Oostvogel HJ. Anorectal symptoms after various modes of vaginal delivery. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):244-9. discussion 9. [pmid: 14530835].
448 Mahony R, Behan M, Daly L, et al. Internal anal sphincter defect influences continence outcome following obstetric anal sphincter injury. Am J Obstet Gynecol. Mar. 2007;196(3):217. e1–5. [pmid: 17346526].
449 Nichols CM, Gill EJ, Nguyen T, et al. Anal sphincter injury in women with pelvic floor disorders. Obstet Gynecol. Oct. 2004;104(4):690-6. [pmid: 15458887].
450 Peschers UM, Sultan AH, Jundt K, et al. Urinary and anal incontinence after vacuum delivery. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2003;110(1):39-42. [pmid: 12932869].
451 Borello-France D, Burgio KL, Richter HE, et al. Fecal and urinary incontinence in primiparous women. Obstet Gynecol. Oct. 2006;108(4):863-72. [pmid: 17012447].
452 Ryden MB, Snyder M, Gross CR, et al. Value-added outcomes: the use of advanced practice nurses in long-term care facilities. Gerontologist. Dec. 2000;40(6):654-62. [pmid: 11131082].
453 Schnelle JF, McNees P, Crooks V, et al. The use of a computer-based model to implement an incontinence management program. Gerontologist. Oct. 1995;35(5):656-65. [pmid: 8543223].
454 Hu TW, Kaltreider DL, Igou JF, et al. Cost effectiveness of training incontinent elderly in nursing homes: a randomized clinical trial. Health Serv Res. Aug. 1990;25(3):455-77. [pmid: 2116385]. [pmcid: 1065639].
455 Hu TW, Igou JF, Kaltreider DL, et al. A clinical trial of a behavioral therapy to reduce urinary incontinence in nursing homes. Outcome and implications. JAMA. May 12. 1989;261(18):2656-62. [pmid: 2496240].
456 Ouslander JG, Greendale GA, Uman G, et al. Effects of oral estrogen and progestin on the lower urinary tract among female nursing home residents. J Am Geriatr Soc. Jun. 2001;49(6):803-7. [pmid: 11454122].
457 Schnelle JF, Traughber B, Sowell VA, et al. Prompted voiding treatment of urinary incontinence in nursing home patients. A behavior management approach for nursing home staff. J Am Geriatr Soc. Nov. 1989;37(11):1051-7. [pmid: 2809052].
458 Ouslander JG, Griffiths PC, McConnell E, et al. Functional incidental training: a randomized, controlled, crossover trial in Veterans Affairs nursing homes. J Am Geriatr Soc. Jul. 2005;53(7):1091-100. [pmid: 16108924].
459 Schnelle JF, Alessi CA, Simmons SF, et al. Translating clinical research into practice: a randomized controlled trial of exercise and incontinence care with nursing home residents. J Am Geriatr Soc. Sep. 2002;50(9):1476-83. [pmid: 12383143].
460 Jirovec MM, Templin T. Predicting success using individualized scheduled toileting for memory-impaired elders at home. Res Nurs Health. Feb. 2001;24(1):1-8. [pmid: 11260580].
461 Colling J, Ouslander J, Hadley BJ, et al. The effects of patterned urge-response toileting (PURT) on urinary incontinence among nursing home residents. J Am Geriatr Soc. Feb. 1992;40(2):135-41. [pmid: 1740597].
462 Wikander B, Ekelund P, Milsom I. An evaluation of multidisciplinary intervention governed by functional independence measure (FIMSM) in incontinent stroke patients. Scand J Rehabil Med. Mar. 1998;30(1):15-21. [pmid: 9526750].
463 Chadha Y, Mollison J, Howie F, et al. Guidelines in gynaecology: evaluation in menorrhagia and in urinary incontinence. BJOG. Apr. 2000;107(4):535-43. [pmid: 10759275].
464 Williams KS, Assassa RP, Cooper NJ, et al. Clinical and cost-effectiveness of a new nurse-led continence service: a randomised controlled trial. Br J Gen Pract. Sep. 2005;55(518):696-703. [pmid: 16176737]. [pmcid: 1464065].
465 Borrie MJ, Bawden M, Speechley M, et al. Interventions led by nurse continence advisers in the management of urinary incontinence: a randomized controlled trial. CMAJ. May 14. 2002;166(10):1267-73. [pmid: 12041843]. [pmcid: 111077].
466 Dowd T, Kolcaba K, Steiner R. Using cognitive strategies to enhance bladder control and comfort. Holist Nurs Pract. Jan. 2000;14(2):91-103. [pmid: 12119974].
467 Moore KH, O'Sullivan RJ, Simons A, et al. Randomised controlled trial of nurse continence advisor therapy compared with standard urogynaecology regimen for conservative incontinence treatment: efficacy, costs and two year follow up. Bjog. Jul. 2003;110(7):649-57. [pmid: 12842055].
468 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: episodes of incontinence and other urinary symptoms. J Aging Health. May. 2000;12(2):250-67. [pmid: 11010699].
469 McFall SL, Yerkes AM, Cowan LD. Outcomes of a small group educational intervention for urinary incontinence: health-related quality of life. J Aging Health. Aug. 2000;12(3):301-17. [pmid: 11067699].
470 Subak LL, Whitcomb E, Shen H, et al. Weight loss: a novel and effective treatment for urinary incontinence. J Urol. Jul. 2005;174(1):190-5. [pmid: 15947625]. [pmcid: 1557356].
471 Dowd TT, Campbell JM, Jones JA. Fluid intake and urinary incontinence in older community-dwelling women. J Community Health Nurs. 1996;13(3):179-86. [pmid: 8916607].
472 Swithinbank L, Hashim H, Abrams P. The effect of fluid intake on urinary symptoms in women. J Urol. Jul. 2005;174(1):187-9. [pmid: 15947624].
473 Tomlinson BU, Dougherty MC, Pendergast JF, et al. Dietary caffeine, fluid intake and urinary incontinence in older rural women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):22-8. [pmid: 10207763].
474 Manonai J, Songchitsomboon S, Chanda K, et al. The effect of a soy-rich diet on urogenital atrophy: a randomized, cross-over trial. Maturitas. May 20. 2006;54(2):135-40. [pmid: 16297576].
475 Brown JS, Wing R, Barrett-Connor E, et al. Lifestyle intervention is associated with lower prevalence of urinary incontinence: the Diabetes Prevention Program. Diabetes Care. Feb. 2006;29(2):385-90. [pmid: 16443892]. [pmcid: 1557353].
476 Bryant CM, Dowell CJ, Fairbrother G. Caffeine reduction education to improve urinary symptoms. Br J Nurs. Apr 25–May 8. 2002;11(8):560-5. [pmid: 11979209].
477 Chiarelli P, Cockburn J. Promoting urinary continence in women after delivery: randomised controlled trial. Bmj. May 25. 2002;324(7348):1241. [pmid: 12028976]. [pmcid: 113274].
478 Reilly ET, Freeman RM, Waterfield MR, et al. Prevention of postpartum stress incontinence in primigravidae with increased bladder neck mobility: a randomised controlled trial of antenatal pelvic floor exercises. Bjog. Jan. 2002;109(1):68-76. [pmid: 11845813].
479 Sampselle CM, Miller JM, Mims BL, et al. Effect of pelvic muscle exercise on transient incontinence during pregnancy and after birth. Obstet Gynecol. Mar. 1998;91(3):406-12. [pmid: 9491869].
480 Chiarelli P, Murphy B, Cockburn J. Promoting urinary continence in postpartum women: 12-month follow-up data from a randomised controlled trial. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):99-105. discussion. [pmid: 15014936].
481 Meyer S, Hohlfeld P, Achtari C, et al. Pelvic floor education after vaginal delivery. Obstet Gynecol. May. 2001;97(5 Pt 1):673-7. [pmid: 11339914].
482 Labrecque M, Eason E, Marcoux S. Randomized trial of perineal massage during pregnancy: perineal symptoms three months after delivery. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):76-80. [pmid: 10649159].
483 Glazener CM, Herbison GP, Wilson PD, et al. Conservative management of persistent postnatal urinary and faecal incontinence: randomised controlled trial. BMJ. Sep 15. 2001;323(7313):593-6. [pmid: 11557703]. [pmcid: 55571].
484 Glazener CM, Herbison GP, MacArthur C, et al. Randomised controlled trial of conservative management of postnatal urinary and faecal incontinence: six year follow up. BMJ. Feb 12. 2005;330(7487):337. [pmid: 15615766]. [pmcid: 548727].
485 Sleep J, Grant A. Pelvic floor exercises in postnatal care. Midwifery. Dec. 1987;3(4):158-64. [pmid: 3320686].
486 Morkved S, Bo K, Schei B, et al. Pelvic floor muscle training during pregnancy to prevent urinary incontinence: a single-blind randomized controlled trial. Obstet Gynecol. Feb. 2003;101(2):313-9. [pmid: 12576255].
487 Diokno AC, Sampselle CM, Herzog AR, et al. Prevention of urinary incontinence by behavioral modification program: a randomized, controlled trial among older women in the community. J Urol. Mar. 2004;171(3):1165-71. [pmid: 14767293].
488 Sampselle CM, Messer KL, Seng JS, et al. Learning outcomes of a group behavioral modification program to prevent urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):441-6. [pmid: 16237512].
489 Dumoulin C, Lemieux MC, Bourbonnais D, et al. Physiotherapy for persistent postnatal stress urinary incontinence: a randomized controlled trial. Obstet Gynecol. Sep. 2004;104(3):504-10. [pmid: 15339760].
490 Goode PS, Burgio KL, Locher JL, et al. Effect of behavioral training with or without pelvic floor electrical stimulation on stress incontinence in women: a randomized controlled trial. JAMA. Jul 16. 2003;290(3):345-52. [pmid: 12865375].
491 Wyman JF, Fantl JA, McClish DK, et al. Comparative efficacy of behavioral interventions in the management of female urinary incontinence. Continence Program for Women Research Group. Am J Obstet Gynecol. Oct. 1998;179(4):999-1007. [pmid: 9790388].
492 Theofrastous JP, Wyman JF, Bump RC, et al. Effects of pelvic floor muscle training on strength and predictors of response in the treatment of urinary incontinence. Neurourol Urodyn. 2002;21(5):486-90. [pmid: 12232886].
493 Alewijnse D, Metsemakers JF, Mesters IE, et al. Effectiveness of pelvic floor muscle exercise therapy supplemented with a health education program to promote long-term adherence among women with urinary incontinence. Neurourol Urodyn. 2003;22(4):284-95. [pmid: 12808702].
494 Aukee P, Immonen P, Laaksonen DE, et al. The effect of home biofeedback training on stress incontinence. Acta Obstet Gynecol Scand. Oct. 2004;83(10):973-7. [pmid: 15453897].
495 Bergman A, Matthews L, Ballard CA. Bladder training after surgery for stress urinary incontinence: is it necessary?. Obstet Gynecol. Dec. 1987;70(6):909-12. [pmid: 3684128].
496 Wang AC, Wang YY, Chen MC. Single-blind, randomized trial of pelvic floor muscle training, biofeedback-assisted pelvic floor muscle training, and electrical stimulation in the management of overactive bladder. Urology. Jan. 2004;63(1):61-6. [pmid: 14751349].
497 Bo K, Kvarstein B, Nygaard I. Lower urinary tract symptoms and pelvic floor muscle exercise adherence after 15 years. Obstet Gynecol. May. 2005;105(5 Pt 1):999-1005. [pmid: 15863536].
498 Elser DM, Wyman JF, McClish DK, et al. The effect of bladder training, pelvic floor muscle training, or combination training on urodynamic parameters in women with urinary incontinence. Continence Program for Women Research Group. Neurourol Urodyn. 1999;18(5):427-36. [pmid: 10494113].
499 Tibaek S, Gard G, Jensen R. Pelvic floor muscle training is effective in women with urinary incontinence after stroke: a randomised, controlled and blinded study. Neurourol Urodyn. 2005;24(4):348-57. [pmid: 15791633].
500 Subak LL, Quesenberry CP, Posner SF, et al. The effect of behavioral therapy on urinary incontinence: a randomized controlled trial. Obstet Gynecol. Jul. 2002;100(1):72-8. [pmid: 12100806].
501 Goode PS, Burgio KL, Locher JL, et al. Urodynamic changes associated with behavioral and drug treatment of urge incontinence in older women. J Am Geriatr Soc. May. 2002;50(5):808-16. [pmid: 12028165].
502 Lagro-Janssen AL, Debruyne FM, Smits AJ, et al. The effects of treatment of urinary incontinence in general practice. Fam Pract. Sep. 1992;9(3):284-9. [pmid: 1459383].
503 Fantl JA, Wyman JF, McClish DK, et al. Efficacy of bladder training in older women with urinary incontinence. JAMA. Feb 6. 1991;265(5):609-13. [pmid: 1987410].
504 Dougherty MC, Dwyer JW, Pendergast JF, et al. A randomized trial of behavioral management for continence with older rural women. Res Nurs Health. Feb. 2002;25(1):3-13. [pmid: 11807915].
505 Burgio KL, Goode PS, Locher JL, et al. Behavioral training with and without biofeedback in the treatment of urge incontinence in older women: a randomized controlled trial. JAMA. Nov 13. 2002;288(18):2293-9. [pmid: 12425706].
506 Wyman JF, Fantl JA, McClish DK, et al. Quality of life following bladder training in older women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):223-9. [pmid: 9449301].
507 Yoon HS, Song HH, Ro YJ. A comparison of effectiveness of bladder training and pelvic muscle exercise on female urinary incontinence. Int J Nurs Stud. Jan. 2003;40(1):45-50. [pmid: 12550149].
508 Janssen CC, Lagro-Janssen AL, Felling AJ. The effects of physiotherapy for female urinary incontinence: individual compared with group treatment. BJU Int. Feb. 2001;87(3):201-6. [pmid: 11167642].
509 Nygaard IE, Kreder KJ, Lepic MM, et al. Efficacy of pelvic floor muscle exercises in women with stress, urge, and mixed urinary incontinence. Am J Obstet Gynecol. Jan. 1996;174(1 Pt 1):120-5. [pmid: 8571994].
510 McClurg D, Ashe RG, Marshall K, et al. Comparison of pelvic floor muscle training, electromyography biofeedback, and neuromuscular electrical stimulation for bladder dysfunction in people with multiple sclerosis: a randomized pilot study. Neurourol Urodyn. 2006;25(4):337-48. [pmid: 16637070].
511 Laycock J, Brown J, Cusack C, et al. Pelvic floor reeducation for stress incontinence: comparing three methods. Br J Community Nurs. May. 2001;6(5):230-7. [pmid: 11893948].
512 Bo K, Talseth T, Vinsnes A. Randomized controlled trial on the effect of pelvic floor muscle training on quality of life and sexual problems in genuine stress incontinent women. Acta Obstet Gynecol Scand. Jul. 2000;79(7):598-603. [pmid: 10929962].
513 Bo K, Talseth T, Holme I. Single blind, randomised controlled trial of pelvic floor exercises, electrical stimulation, vaginal cones, and no treatment in management of genuine stress incontinence in women. BMJ. Feb 20. 1999;318(7182):487-93. [pmid: 10024253]. [pmcid: 27740].
514 Cammu H, Van Nylen M. Pelvic floor exercises versus vaginal weight cones in genuine stress incontinence. Eur J Obstet Gynecol Reprod Biol. Mar. 1998;77(1):89-93. [pmid: 9550207].
515 Miller JM, Ashton-Miller JA, DeLancey JO. A pelvic muscle precontraction can reduce cough-related urine loss in selected women with mild SUI. J Am Geriatr Soc. Jul. 1998;46(7):870-4. [pmid: 9670874].
516 Aksac B, Aki S, Karan A, et al. Biofeedback and pelvic floor exercises for the rehabilitation of urinary stress incontinence. Gynecol Obstet Invest. 2003;56(1):23-7. [pmid: 12867764].
517 Burns PA, Pranikoff K, Nochajski TH, et al. A comparison of effectiveness of biofeedback and pelvic muscle exercise treatment of stress incontinence in older community-dwelling women. J Gerontol. Jul. 1993;48(4):M167-74. [pmid: 8315230].
518 Sherman RA, Davis GD, Wong MF. Behavioral treatment of exercise-induced urinary incontinence among female soldiers. Mil Med. Oct. 1997;162(10):690-4. [pmid: 9339085].
519 Burns PA, Pranikoff K, Nochajski T, et al. Treatment of stress incontinence with pelvic floor exercises and biofeedback. J Am Geriatr Soc. Mar. 1990;38(3):341-4. [pmid: 2179379].
520 Wells TJ, Brink CA, Diokno AC, et al. Pelvic muscle exercise for stress urinary incontinence in elderly women. J Am Geriatr Soc. Aug. 1991;39(8):785-91. [pmid: 2071809].
521 Aukee P, Immonen P, Penttinen J, et al. Increase in pelvic floor muscle activity after 12 weeks' training: a randomized prospective pilot study. Urology. Dec. 2002;60(6):1020-3. discussion 3–4. [pmid: 12475661].
522 Berghmans LC, Frederiks CM, de Bie RA, et al. Efficacy of biofeedback, when included with pelvic floor muscle exercise treatment, for genuine stress incontinence. Neurourol Urodyn. 1996;15(1):37-52. [pmid: 8696355].
523 Liebergall-Wischnitzer M, Hochner-Celnikier D, Lavy Y, et al. Paula method of circular muscle exercises for urinary stress incontinence—a clinical trial. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):345-51. [pmid: 15660184].
524 Sung MS, Choi YH, Back SH, et al. The effect of pelvic floor muscle exercises on genuine stress incontinence among Korean women—focusing on its effects on the quality of life. Yonsei Med J. Apr. 2000;41(2):237-51. [pmid: 10817026].
525 Lagro-Janssen TL, Debruyne FM, Smits AJ, et al. Controlled trial of pelvic floor exercises in the treatment of urinary stress incontinence in general practice. Br J Gen Pract. Nov. 1991;41(352):445-9. [pmid: 1807303]. [pmcid: 1371786].
526 Kim JI. Continence efficacy intervention program for community residing women with stress urinary incontinence in Japan. Public Health Nurs. Jan–Feb. 2001;18(1):64-72. [pmid: 11251875].
527 Arvonen T, Fianu-Jonasson A, Tyni-Lenne R. Effectiveness of two conservative modes of physical therapy in women with urinary stress incontinence. Neurourol Urodyn. 2001;20(5):591-9. [pmid: 11574936].
528 Borello-France DF, Zyczynski HM, Downey PA, et al. Effect of pelvic-floor muscle exercise position on continence and quality-of-life outcomes in women with stress urinary incontinence. Phys Ther. Jul. 2006;86(7):974-86. [pmid: 16813477].
529 Morkved S, Bo K, Fjortoft T. Effect of adding biofeedback to pelvic floor muscle training to treat urodynamic stress incontinence. Obstet Gynecol. Oct. 2002;100(4):730-9. [pmid: 12383542].
530 Wille S, Sobottka A, Heidenreich A, et al. Pelvic floor exercises, electrical stimulation and biofeedback after radical prostatectomy: results of a prospective randomized trial. J Urol. Aug. 2003;170(2 Pt 1):490-3. [pmid: 12853806].
531 Yokoyama T, Nishiguchi J, Watanabe T, et al. Comparative study of effects of extracorporeal magnetic innervation versus electrical stimulation for urinary incontinence after radical prostatectomy. Urology. Feb. 2004;63(2):264-7. [pmid: 14972468].
532 Filocamo MT, Li Marzi V, Del Popolo G, et al. Effectiveness of early pelvic floor rehabilitation treatment for post-prostatectomy incontinence. Eur Urol. Nov. 2005;48(5):734-8. [pmid: 16002204].
533 Moore KN, Griffiths D, Hughton A. Urinary incontinence after radical prostatectomy: a randomized controlled trial comparing pelvic muscle exercises with or without electrical stimulation. BJU Int. Jan. 1999;83(1):57-65. [pmid: 10233453].
534 Mathewson-Chapman M. Pelvic muscle exercise/biofeedback for urinary incontinence after prostatectomy: an education program. J Cancer Educ. Winter. 1997;12(4):218-23. [pmid: 9440013].
535 Floratos DL, Sonke GS, Rapidou CA, et al. Biofeedback vs verbal feedback as learning tools for pelvic muscle exercises in the early management of urinary incontinence after radical prostatectomy. BJU Int. May. 2002;89(7):714-9. [pmid: 11966630].
536 Van Kampen M, De Weerdt W, Van Poppel H, et al. Effect of pelvic-floor re-education on duration and degree of incontinence after radical prostatectomy: a randomised controlled trial. Lancet. Jan 8. 2000;355(9198):98-102. [pmid: 10675166].
537 Bales GT, Gerber GS, Minor TX, et al. Effect of preoperative biofeedback/pelvic floor training on continence in men undergoing radical prostatectomy. Urology. Oct 1. 2000;56(4):627-30. [pmid: 11018619].
538 Porru D, Campus G, Caria A, et al. Impact of early pelvic floor rehabilitation after transurethral resection of the prostate. Neurourol Urodyn. 2001;20(1):53-9. [pmid: 11135382].
539 Franke JJ, Gilbert WB, Grier J, et al. Early post-prostatectomy pelvic floor biofeedback. J Urol. Jan. 2000;163(1):191-3. [pmid: 10604344].
540 Parekh AR, Feng MI, Kirages D, et al. The role of pelvic floor exercises on post-prostatectomy incontinence. J Urol. Jul. 2003;170(1):130-3. [pmid: 12796664].
541 Dorey G, Speakman M, Feneley R, et al. Pelvic floor exercises for treating post-micturition dribble in men with erectile dysfunction: a randomized controlled trial. Urol Nurs 2004 Dec; 24(6):490–7, 512.
542 Burgio KL, Goode PS, Urban DA, et al. Preoperative biofeedback assisted behavioral training to decrease post-prostatectomy incontinence: a randomized, controlled trial. J Urol. Jan. 2006;175(1):196-201. discussion. [pmid: 16406909].
543 McDowell BJ, Engberg S, Sereika S, et al. Effectiveness of behavioral therapy to treat incontinence in homebound older adults. J Am Geriatr Soc. Mar. 1999;47(3):309-18. [pmid: 10078893].
544 Engberg S, Sereika SM, McDowell BJ, et al. Effectiveness of prompted voiding in treating urinary incontinence in cognitively impaired homebound older adults. J Wound Ostomy Continence Nurs. Sep. 2002;29(5):252-65. [pmid: 12510471].
545 Paterson J, Pinnock CB, Marshall VR. Pelvic floor exercises as a treatment for post-micturition dribble. Br J Urol. Jun. 1997;79(6):892-7. [pmid: 9202555].
546 But I. Conservative treatment of female urinary incontinence with functional magnetic stimulation. Urology. Mar. 2003;61(3):558-61. [pmid: 12639647].
547 Spruijt J, Vierhout M, Verstraeten R, et al. Vaginal electrical stimulation of the pelvic floor: a randomized feasibility study in urinary incontinent elderly women. Acta Obstet Gynecol Scand. Nov. 2003;82(11):1043-8. [pmid: 14616279].
548 Yamanishi T, Yasuda K, Sakakibara R, et al. Randomized, double-blind study of electrical stimulation for urinary incontinence due to detrusor overactivity. Urology. Mar. 2000;55(3):353-7. [pmid: 10699609].
549 Yamanishi T, Sakakibara R, Uchiyama T, et al. Comparative study of the effects of magnetic versus electrical stimulation on inhibition of detrusor overactivity. Urology. Nov 1. 2000;56(5):777-81. [pmid: 11068300].
550 Lappin MS, Lawrie FW, Richards TL, et al. Effects of a pulsed electromagnetic therapy on multiple sclerosis fatigue and quality of life: a double-blind, placebo controlled trial. Altern Ther Health Med. Jul–Aug. 2003;9(4):38-48.
551 Amaro JL, Gameiro MO, Kawano PR, et al. Intravaginal electrical stimulation: a randomized, double-blind study on the treatment of mixed urinary incontinence. Acta Obstet Gynecol Scand. 2006;85(5):619-22. [pmid: 16752244].
552 Berghmans B, van Waalwijk van Doorn E, Nieman F, et al. Efficacy of physical therapeutic modalities in women with proven bladder overactivity. Eur Urol. Jun. 2002;41(6):581-7. [pmid: 12074773].
553 Pages IH, Jahr S, Schaufele MK, et al. Comparative analysis of biofeedback and physical therapy for treatment of urinary stress incontinence in women. Am J Phys Med Rehabil. Jul. 2001;80(7):494-502. [pmid: 11421517].
554 Sand PK, Richardson DA, Staskin DR, et al. Pelvic floor electrical stimulation in the treatment of genuine stress incontinence: a multicenter, placebo-controlled trial. Am J Obstet Gynecol. Jul. 1995;173(1):72-9. [pmid: 7631730].
555 Indrekvam S, Sandvik H, Hunskaar S. A Norwegian national cohort of 3198 women treated with home-managed electrical stimulation for urinary incontinence—effectiveness and treatment results. Scand J Urol Nephrol. Feb. 2001;35(1):32-9. [pmid: 11291684].
556 Smith JJ 3rd. Intravaginal stimulation randomized trial. J Urol. Jan. 1996;155(1):127-30. [pmid: 7490809].
557 Brubaker L, Benson JT, Bent A, et al. Transvaginal electrical stimulation for female urinary incontinence. Am J Obstet Gynecol. Sep. 1997;177(3):536-40. [pmid: 9322620].
558 Amaro JL, Gameiro MO, Padovani CR. Effect of intravaginal electrical stimulation on pelvic floor muscle strength. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):355-8. [pmid: 15647885].
559 But I, Faganelj M, Sostaric A. Functional magnetic stimulation for mixed urinary incontinence. J Urol. May. 2005;173(5):1644-6. [pmid: 15821527].
560 Bo K, Talseth T. Change in urethral pressure during voluntary pelvic floor muscle contraction and vaginal electrical stimulation. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(1):3-6. discussion -7. [pmid: 9260089].
561 Luber KM, Wolde-Tsadik G. Efficacy of functional electrical stimulation in treating genuine stress incontinence: a randomized clinical trial. Neurourol Urodyn. 1997;16(6):543-51. [pmid: 9353803].
562 Emmons SL, Otto L. Acupuncture for overactive bladder: a randomized controlled trial. Obstet Gynecol. Jul. 2005;106(1):138-43. [pmid: 15994629].
563 Yamanishi T, Yasuda K, Sakakibara R, et al. Pelvic floor electrical stimulation in the treatment of stress incontinence: an investigational study and a placebo controlled double-blind trial. J Urol. Dec. 1997;158(6):2127-31. [pmid: 9366328].
564 Barroso JC, Ramos JG, Martins-Costa S, et al. Transvaginal electrical stimulation in the treatment of urinary incontinence. BJU Int. Feb. 2004;93(3):319-23. [pmid: 14764129].
565 Scheepens WA, de Bie RA, Weil EH, et al. Unilateral versus bilateral sacral neuromodulation in patients with chronic voiding dysfunction. J Urol. Nov. 2002;168(5):2046-50. [pmid: 12394705].
566 Schmidt RA, Jonas U, Oleson KA, et al. Sacral nerve stimulation for treatment of refractory urinary urge incontinence. Sacral Nerve Stimulation Study Group. J Urol. Aug. 1999;162(2):352-7. [pmid: 10411037].
567 Weil EH, Ruiz-Cerda JL, Eerdmans PH, et al. Sacral root neuromodulation in the treatment of refractory urinary urge incontinence: a prospective randomized clinical trial. Eur Urol. Feb. 2000;37(2):161-71. [pmid: 10705194].
568 Karademir K, Baykal K, Sen B, et al. A peripheric neuromodulation technique for curing detrusor overactivity: Stoller afferent neurostimulation. Scand J Urol Nephrol. 2005;39(3):230-3. [pmid: 16118096].
569 Bower WF, Moore KH, Adams RD, et al. A urodynamic study of surface neuromodulation versus sham in detrusor instability and sensory urgency. J Urol. Dec. 1998;160(6 Pt 1):2133-6. [pmid: 9817339].
570 Fujishiro T, Enomoto H, Ugawa Y, et al. Magnetic stimulation of the sacral roots for the treatment of stress incontinence: an investigational study and placebo controlled trial. J Urol. Oct. 2000;164(4):1277-9. [pmid: 10992380].
571 Fujishiro T, Takahashi S, Enomoto H, et al. Magnetic stimulation of the sacral roots for the treatment of urinary frequency and urge incontinence: an investigational study and placebo controlled trial. J Urol. Sep. 2002;168(3):1036-9. [pmid: 12187217].
572 Walsh IK, Thompson T, Loughridge WG, et al. Non-invasive antidromic neurostimulation: a simple effective method for improving bladder storage. Neurourol Urodyn. 2001;20(1):73-84. [pmid: 11135384].
573 Borawski KM, Foster RT, Webster GD, et al. Predicting implantation with a neuromodulator using two different test stimulation techniques: A prospective randomized study in urge incontinent women. Neurourol Urodyn. 2007;26(1):14-8. [pmid: 17123297].
574 Stamp G, Kruzins G, Crowther C. Perineal massage in labour and prevention of perineal trauma: randomised controlled trial. Bmj. May 26. 2001;322(7297):1277-80. [pmid: 11375230]. [pmcid: 31922].
575 Jarvis SK, Hallam TK, Lujic S, et al. Peri-operative physiotherapy improves outcomes for women undergoing incontinence and or prolapse surgery: results of a randomised controlled trial. Aust N Z J Obstet Gynaecol. Aug. 2005;45(4):300-3. [pmid: 16029296].
576 Nygaard I. Prevention of exercise incontinence with mechanical devices. J Reprod Med. Feb. 1995;40(2):89-94. [pmid: 7738934].
577 Thyssen H, Bidmead J, Lose G, et al. A new intravaginal device for stress incontinence in women. BJU Int. Dec. 2001;88(9):889-92. [pmid: 11851609].
578 Seo JT, Yoon H, Kim YH. A randomized prospective study comparing new vaginal cone and FES-Biofeedback. Yonsei Med J. Oct 31. 2004;45(5):879-84. [pmid: 15515199].
579 Robinson H, Schulz J, Flood C, et al. A randomized controlled trial of the NEAT expandable tip continence device. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):199-203. discussion. [pmid: 12955343].
580 Nielsen KK, Walter S, Maegaard E, et al. The urethral plug II: an alternative treatment in women with genuine urinary stress incontinence. Br J Urol. Oct. 1993;72(4):428-32. [pmid: 8261298].
581 Chancellor MB, Bennett C, Simoneau AR, et al. Sphincteric stent versus external sphincterotomy in spinal cord injured men: prospective randomized multicenter trial. J Urol. Jun. 1999;161(6):1893-8. [pmid: 10332461].
582 Moore KN, Schieman S, Ackerman T, et al. Assessing comfort, safety, and patient satisfaction with three commonly used penile compression devices. Urology. Jan. 2004;63(1):150-4. [pmid: 14751370].
583 Corcos J, Collet JP, Shapiro S, et al. Multicenter randomized clinical trial comparing surgery and collagen injections for treatment of female stress urinary incontinence. Urology. May. 2005;65(5):898-904. [pmid: 15882720].
584 Bano F, Barrington JW, Dyer R. Comparison between porcine dermal implant (Permacol) and silicone injection (Macroplastique) for urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):147-50. discussion 50. [pmid: 15378234].
585 Schulz JA, Nager CW, Stanton SL, et al. Bulking agents for stress urinary incontinence: short-term results and complications in a randomized comparison of periurethral and transurethral injections. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):261-5. [pmid: 15517671].
586 Lightner D, Calvosa C, Andersen R, et al. A new injectable bulking agent for treatment of stress urinary incontinence: results of a multicenter, randomized, controlled, double-blind study of Durasphere. Urology. Jul. 2001;58(1):12-5. [pmid: 11445471].
587 Appell RA, Juma S, Wells WG, et al. Transurethral radiofrequency energy collagen micro-remodeling for the treatment of female stress urinary incontinence. Neurourol Urodyn. 2006;25(4):331-6. [pmid: 16673379].
588 Lee PE, Kung RC, Drutz HP. Periurethral autologous fat injection as treatment for female stress urinary incontinence: a randomized double-blind controlled trial. J Urol. Jan. 2001;165(1):153-8. [pmid: 11125386].
589 Strasser H, Marksteiner R, Margreiter E, et al. Autologous myoblasts and fibroblasts versus collagen for treatment of stress urinary incontinence in women: a randomised controlled trial. Lancet. Jun 30. 2007;369(9580):2179-86. [pmid: 17604800].
590 Dannecker C, Hillemanns P, Strauss A, et al. Episiotomy and perineal tears presumed to be imminent: the influence on the urethral pressure profile, analmanometric and other pelvic floor findings—follow-up study of a randomized controlled trial. Acta Obstet Gynecol Scand. Jan. 2005;84(1):65-71. [pmid: 15603570].
591 Sartore A, De Seta F, Maso G, et al. The effects of mediolateral episiotomy on pelvic floor function after vaginal delivery. Obstet Gynecol. Apr. 2004;103(4):669-73. [pmid: 15051557].
592 Hannah ME, Hannah WJ, Hodnett ED, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. Jama. Apr 10. 2002;287(14):1822-31. [pmid: 11939868].
593 Hannah ME, Whyte H, Hannah WJ, et al. Maternal outcomes at 2 years after planned cesarean section versus planned vaginal birth for breech presentation at term: the international randomized Term Breech Trial. Am J Obstet Gynecol. Sep. 2004;191(3):917-27. [pmid: 15467565].
594 Klein MC, Kaczorowski J, Firoz T, et al. A comparison of urinary and sexual outcomes in women experiencing vaginal and Caesarean births. J Obstet Gynaecol Can. Apr. 2005;27(4):332-9. [pmid: 15937606].
595 Sleep J, Grant A. West Berkshire perineal management trial: three year follow up. Br Med J (Clin Res Ed). Sep 26. 1987;295(6601):749-51.
596 Johanson RB, Heycock E, Carter J, et al. Maternal and child health after assisted vaginal delivery: five-year follow up of a randomised controlled study comparing forceps and ventouse. Br J Obstet Gynaecol. Jun. 1999;106(6):544-9. [pmid: 10426611].
597 Garcia V, Rogers RG, Kim SS, et al. Primary repair of obstetric anal sphincter laceration: a randomized trial of two surgical techniques. Am J Obstet Gynecol. May. 2005;192(5):1697-701. [pmid: 15902180].
598 Gimbel H, Zobbe V, Andersen BM, et al. Randomised controlled trial of total compared with subtotal hysterectomy with one-year follow up results. Bjog. Dec. 2003;110(12):1088-98. [pmid: 14664880].
599 Thakar R, Ayers S, Clarkson P, et al. Outcomes after total versus subtotal abdominal hysterectomy. N Engl J Med. Oct 24. 2002;347(17):1318-25. [pmid: 12397189].
600 Lalos O, Bjerle P. Bladder wall mechanics and micturition before and after subtotal and total hysterectomy. Eur J Obstet Gynecol Reprod Biol. Mar. 1986;21(3):143-50. [pmid: 3956833].
601 Kaya H, Sezik M, Ozbasar D, et al. Intrafascial versus extrafascial abdominal hysterectomy: effects on urinary urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):171-4. [pmid: 15167995].
602 Learman LA, Summitt RL Jr, Varner RE, et al. A randomized comparison of total or supracervical hysterectomy: surgical complications and clinical outcomes. Obstet Gynecol. Sep. 2003;102(3):453-62. [pmid: 12962924].
603 Long CY, Liu CM, Wu TP, et al. A randomized comparison of vesicourethral function after laparoscopic hysterectomy with and without vaginal cuff suspension. J Minim Invasive Gynecol. Mar–Apr. 2005;12(2):137-43. [pmid: 15904617].
604 Schraffordt Koops SE, Bisseling TM, Heintz AP, et al. The effectiveness of tension-free vaginal tape (TVT) and quality of life measured in women with previous urogynecologic surgery: analysis from The Netherlands TVT database. Am J Obstet Gynecol. Aug. 2006;195(2):439-44. [pmid: 16635472].
605 Rafii A, Paoletti X, Haab F, et al. Tension-free vaginal tape and associated procedures: a case control study. Eur Urol. Mar. 2004;45(3):356-61. [pmid: 15036683].
606 Rechberger T, Rzezniczuk K, Skorupski P, et al. A randomized comparison between monofilament and multifilament tapes for stress incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):432-6. [pmid: 14677007].
607 Wadie BS, Edwan A, Nabeeh AM. Autologous fascial sling vs polypropylene tape at short-term followup: a prospective randomized study. J Urol. Sep. 2005;174(3):990-3. [pmid: 16094020].
608 Adamiak A, Milart P, Skorupski P, et al. The efficacy and safety of the tension-free vaginal tape procedure do not depend on the method of analgesia. Eur Urol. Jul. 2002;42(1):29-33. [pmid: 12121726].
609 Ward K, Hilton P. Prospective multicentre randomised trial of tension-free vaginal tape and colposuspension as primary treatment for stress incontinence. BMJ. Jul 13. 2002;325(7355):67. [pmid: 12114234]. [pmcid: 117136].
610 Valpas A, Kivela A, Penttinen J, et al. Tension-free vaginal tape and laparoscopic mesh colposuspension for stress urinary incontinence. Obstet Gynecol. Jul. 2004;104(1):42-9. [pmid: 15228999].
611 Valpas A, Kivela A, Penttinen J, et al. Tension-free vaginal tape and laparoscopic mesh colposuspension in the treatment of stress urinary incontinence: immediate outcome and complications—a randomized clinical trial. Acta Obstet Gynecol Scand. Jul. 2003;82(7):665-71. [pmid: 12790850].
612 deTayrac R, Deffieux X, Droupy S, et al. A prospective randomized trial comparing tension-free vaginal tape and transobturator suburethral tape for surgical treatment of stress urinary incontinence. Am J Obstet Gynecol. Mar. 2004;190(3):602-8. [pmid: 15041987].
613 Andonian S, Chen T, St-Denis B, et al. Randomized clinical trial comparing suprapubic arch sling (SPARC) and tension-free vaginal tape (TVT): one-year results. Eur Urol. Apr. 2005;47(4):537-41. [pmid: 15774255].
614 Lim YN, Muller R, Corstiaans A, et al. Suburethral slingplasty evaluation study in North Queensland, Australia: the SUSPEND trial. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):52-9. [pmid: 15730366].
615 Lord HE, Taylor JD, Finn JC, et al. A randomized controlled equivalence trial of short-term complications and efficacy of tension-free vaginal tape and suprapubic urethral support sling for treating stress incontinence. BJU Int. Aug. 2006;98(2):367-76. [pmid: 16879679].
616 Meschia M, Pifarotti P, Bernasconi F, et al. Tension-free vaginal tape (TVT) and intravaginal slingplasty (IVS) for stress urinary incontinence: a multicenter randomized trial. Am J Obstet Gynecol. Nov. 2006;195(5):1338-42. [pmid: 16769016].
617 Arunkalaivanan AS, Barrington JW. Randomized trial of porcine dermal sling (Pelvicol implant) vs. tension-free vaginal tape (TVT) in the surgical treatment of stress incontinence: a questionnaire-based study. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):17-23. discussion 1–2. [pmid: 12601511].
618 David-Montefiore E, Frobert JL, Grisard-Anaf M, et al. Peri-operative complications and pain after the suburethral sling procedure for urinary stress incontinence: a French prospective randomised multicentre study comparing the retropubic and transobturator routes. Eur Urol. Jan. 2006;49(1):133-8. [pmid: 16310932].
619 Dietz HP, Barry C, Lim YN, et al. Two-dimensional and three-dimensional ultrasound imaging of suburethral slings. Ultrasound Obstet Gynecol. Aug. 2005;26(2):175-9. [pmid: 15988786].
620 Maher CF, O'Reilly BA, Dwyer PL, et al. Pubovaginal sling versus transurethral Macroplastique for stress urinary incontinence and intrinsic sphincter deficiency: a prospective randomised controlled trial. BJOG. Jun. 2005;112(6):797-801. [pmid: 15924540].
621 Abdel-Fattah M, Barrington JW, Arunkalaivanan AS. Pelvicol pubovaginal sling versus tension-free vaginal tape for treatment of urodynamic stress incontinence: a prospective randomized three-year follow-up study. Eur Urol. Nov. 2004;46(5):629-35. [pmid: 15474274].
622 Darai E, Frobert JL, Grisard-Anaf M, et al. Functional results after the suburethral sling procedure for urinary stress incontinence: a prospective randomized multicentre study comparing the retropubic and transobturator routes. Eur Urol. Mar. 2007;51(3):795-801. discussion -2. [pmid: 17010507].
623 Choe JM, Ogan K, Battino BS. Antimicrobial mesh versus vaginal wall sling: a comparative outcomes analysis. J Urol. Jun. 2000;163(6):1829-34. [pmid: 10799192].
624 Kuo HC. Comparison of video urodynamic results after the pubovaginal sling procedure using rectus fascia and polypropylene mesh for stress urinary incontinence. J Urol. Jan. 2001;165(1):163-8. [pmid: 11125388].
625 Cholhan HJ, Lotze PM. Voiding function after a modified no-tension pubovaginal sling. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):249-56. [pmid: 15517669].
626 Hilton P. A clinical and urodynamic study comparing the Stamey bladder neck suspension and suburethral sling procedures in the treatment of genuine stress incontinence. Br J Obstet Gynaecol. Feb. 1989;96(2):213-20. [pmid: 2930745].
627 Tseng LH, Wang AC, Lin YH, et al. Randomized comparison of the suprapubic arc sling procedure vs tension-free vaginal taping for stress incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):230-5. [pmid: 15875240].
628 Barbalias G, Liatsikos E, Barbalias D. Use of slings made of indigenous and allogenic material (Goretex) in type III urinary incontinence and comparison between them. Eur Urol. 1997;31(4):394-400. [pmid: 9187896].
629 Laurikainen E, Valpas A, Kivela A, et al. Retropubic compared with transobturator tape placement in treatment of urinary incontinence: a randomized controlled trial. Obstet Gynecol. Jan. 2007;109(1):4-11. [pmid: 17197581].
630 Ward KL, Hilton P. A prospective multicenter randomized trial of tension-free vaginal tape and colposuspension for primary urodynamic stress incontinence: two-year follow-up. Am J Obstet Gynecol. Feb. 2004;190(2):324-31. [pmid: 14981369].
631 Meschia M, Pifarotti P, Spennacchio M, et al. A randomized comparison of tension-free vaginal tape and endopelvic fascia plication in women with genital prolapse and occult stress urinary incontinence. Am J Obstet Gynecol. Mar. 2004;190(3):609-13. [pmid: 15041988].
632 Zullo MA, Plotti F, Calcagno M, et al. Vaginal estrogen therapy and overactive bladder symptoms in postmenopausal patients after a tension-free vaginal tape procedure: a randomized clinical trial. Menopause. Jul–Aug. 2005;12(4):421-7. [pmid: 16037757].
633 Colombo M, Maggioni A, Zanetta G, et al. Prevention of postoperative urinary stress incontinence after surgery for genitourinary prolapse. Obstet Gynecol. Feb. 1996;87(2):266-71. [pmid: 8559537].
634 Brubaker L, Cundiff GW, Fine P, et al. Abdominal sacrocolpopexy with Burch colposuspension to reduce urinary stress incontinence. N Engl J Med. Apr 13. 2006;354(15):1557-66. [pmid: 16611949].
635 Bump RC, Hurt WG, Theofrastous JP, et al. Randomized prospective comparison of needle colposuspension versus endopelvic fascia plication for potential stress incontinence prophylaxis in women undergoing vaginal reconstruction for stage III or IV pelvic organ prolapse. The Continence Program for Women Research Group. Am J Obstet Gynecol. Aug. 1996;175(2):326-33. discussion 33–5. [pmid: 8765249].
636 Colombo M, Maggioni A, Scalambrino S, et al. Surgery for genitourinary prolapse and stress incontinence: a randomized trial of posterior pubourethral ligament plication and Pereyra suspension. Am J Obstet Gynecol. Feb. 1997;176(2):337-43. [pmid: 9065178].
637 Roovers JP, van der Vaart CH, van der Bom JG, et al. A randomised controlled trial comparing abdominal and vaginal prolapse surgery: effects on urogenital function. Bjog. Jan. 2004;111(1):50-6. [pmid: 14687052].
638 Sand PK, Winkler H, Blackhurst DW, et al. A prospective randomized study comparing modified Burch retropubic urethropexy and suburethral sling for treatment of genuine stress incontinence with low-pressure urethra. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):30-4. [pmid: 10649153].
639 Demirci F, Yucel O. Comparison of pubovaginal sling and burch colposuspension procedures in type I/II genuine stress incontinence. Arch Gynecol Obstet. Nov. 2001;265(4):190-4. [pmid: 11789743].
640 Culligan PJ, Goldberg RP, Sand PK. A randomized controlled trial comparing a modified Burch procedure and a suburethral sling: long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):229-33. discussion 33. [pmid: 14530832].
641 Bai SW, Sohn WH, Chung DJ, et al. Comparison of the efficacy of Burch colposuspension, pubovaginal sling, and tension-free vaginal tape for stress urinary incontinence. Int J Gynaecol Obstet. Dec. 2005;91(3):246-51. [pmid: 16242695].
642 Liapis A, Bakas P, Creatsas G. Burch colposuspension and tension-free vaginal tape in the management of stress urinary incontinence in women. Eur Urol. Apr. 2002;41(4):469-73. [pmid: 12074820].
643 Paraiso MF, Walters MD, Karram MM, et al. Laparoscopic Burch colposuspension versus tension-free vaginal tape: a randomized trial. Obstet Gynecol. Dec. 2004;104(6):1249-58. [pmid: 15572485].
644 Ustun Y, Engin-Ustun Y, Gungor M, et al. Tension-free vaginal tape compared with laparoscopic Burch urethropexy. J Am Assoc Gynecol Laparosc. Aug. 2003;10(3):386-9. [pmid: 14567818].
645 El-Barky E, El-Shazly A, El-Wahab OA, et al. Tension free vaginal tape versus Burch colposuspension for treatment of female stress urinary incontinence. Int Urol Nephrol. 2005;37(2):277-81. [pmid: 16142556].
646 Wang AC, Chen MC. Comparison of tension-free vaginal taping versus modified Burch colposuspension on urethral obstruction: a randomized controlled trial. Neurourol Urodyn. 2003;22(3):185-90. [pmid: 12707868].
647 Colombo M, Milani R, Vitobello D, et al. A randomized comparison of Burch colposuspension and abdominal paravaginal defect repair for female stress urinary incontinence. Am J Obstet Gynecol. Jul. 1996;175(1):78-84. [pmid: 8694079].
648 Gilja I, Puskar D, Mazuran B, et al. Comparative analysis of bladder neck suspension using Raz, Burch and transvaginal Burch procedures. A 3-year randomized prospective study. Eur Urol. 1998;33(3):298-302. [pmid: 9555556].
649 Berglund AL, Lalos O. The pre- and postsurgical nursing of women with stress incontinence. J Adv Nurs. Mar. 1996;23(3):502-11. [pmid: 8655825].
650 Lalos O, Berglund AL, Bjerle P. Urodynamics in women with stress incontinence before and after surgery. Eur J Obstet Gynecol Reprod Biol. Mar. 1993;48(3):197-205. [pmid: 8335138].
651 Osman T. Stress incontinence surgery for patients presenting with mixed incontinence and a normal cystometrogram. BJU Int. Dec. 2003;92(9):964-8. [pmid: 14632856].
652 Costantini E, Zucchi A, Giannantoni A, et al. Must colposuspension be associated with sacropexy to prevent postoperative urinary incontinence?. Eur Urol. Mar. 2007;51(3):788-94. [pmid: 17011699].
653 Persson J, Teleman P, Eten-Bergquist C, et al. Cost-analyzes based on a prospective, randomized study comparing laparoscopic colposuspension with a tension-free vaginal tape procedure. Acta Obstet Gynecol Scand. Nov. 2002;81(11):1066-73. [pmid: 12421176].
654 Fatthy H, El Hao M, Samaha I, et al. Modified Burch colposuspension: laparoscopy versus laparotomy. J Am Assoc Gynecol Laparosc. Feb. 2001;8(1):99-106. [pmid: 11172123].
655 Kitchener HC, Dunn G, Lawton V, et al. Laparoscopic versus open colposuspension—results of a prospective randomised controlled trial. BJOG. Sep. 2006;113(9):1007-13. [pmid: 16956332].
656 Cheon WC, Mak JH, Liu JY. Prospective randomised controlled trial comparing laparoscopic and open colposuspension. Hong Kong Med J. Feb. 2003;9(1):10-4. [pmid: 12547950].
657 Su TH, Wang KG, Hsu CY, et al. Prospective comparison of laparoscopic and traditional colposuspensions in the treatment of genuine stress incontinence. Acta Obstet Gynecol Scand. Jul. 1997;76(6):576-82. [pmid: 9246967].
658 German KA, Kynaston H, Weight S, et al. A prospective randomized trial comparing a modified needle suspension procedure with the vagina/obturator shelf procedure for genuine stress incontinence. Br J Urol. Aug. 1994;74(2):188-90. [pmid: 7921936].
659 Zullo F, Morelli M, Russo T, et al. Two techniques of laparoscopic retropubic urethropexy. J Am Assoc Gynecol Laparosc. May. 2002;9(2):178-81. [pmid: 11960044].
660 Colombo M, Vitobello D, Proietti F, et al. Randomised comparison of Burch colposuspension versus anterior colporrhaphy in women with stress urinary incontinence and anterior vaginal wall prolapse. Bjog. Apr. 2000;107(4):544-51. [pmid: 10759276].
661 Quadri G, Magatti F, Belloni C, et al. Marshall-Marchetti-Krantz urethropexy and Burch colposuspension for stress urinary incontinence in women with low pressure and hypermobility of the urethra: early results of a prospective randomized clinical trial. Am J Obstet Gynecol. Jul. 1999;181(1):12-8. [pmid: 10411835].
662 Colombo M, Scalambrino S, Maggioni A, et al. Burch colposuspension versus modified Marshall-Marchetti-Krantz urethropexy for primary genuine stress urinary incontinence: a prospective, randomized clinical trial. Am J Obstet Gynecol. Dec. 1994;171(6):1573-9. [pmid: 7802070].
663 Bergman A, Elia G. Three surgical procedures for genuine stress incontinence: five-year follow-up of a prospective randomized study. Am J Obstet Gynecol. Jul. 1995;173(1):66-71. [pmid: 7631729].
664 Kammerer-Doak DN, Dorin MH, Rogers RG, et al. A randomized trial of burch retropubic urethropexy and anterior colporrhaphy for stress urinary incontinence. Obstet Gynecol. Jan. 1999;93(1):75-8. [pmid: 9916960].
665 Bergman A, Ballard CA, Koonings PP. Comparison of three different surgical procedures for genuine stress incontinence: prospective randomized study. Am J Obstet Gynecol. May. 1989;160(5 Pt 1):1102-6. [pmid: 2729386].
666 Persson J, Wolner-Hanssen P. Laparoscopic Burch colposuspension for stress urinary incontinence: a randomized comparison of one or two sutures on each side of the urethra. Obstet Gynecol. Jan. 2000;95(1):151-5. [pmid: 10636519].
667 Zullo F, Palomba S, Piccione F, et al. Laparoscopic Burch colposuspension: a randomized controlled trial comparing two transperitoneal surgical techniques. Obstet Gynecol. Nov. 2001;98(5 Pt 1):783-8. [pmid: 11704169].
668 Ankardal M, Milsom I, Stjerndahl JH, et al. A three-armed randomized trial comparing open Burch colposuspension using sutures with laparoscopic colposuspension using sutures and laparoscopic colposuspension using mesh and staples in women with stress urinary incontinence. Acta Obstet Gynecol Scand. Aug. 2005;84(8):773-9. [pmid: 16026404].
669 Ankardal M, Ekerydh A, Crafoord K, et al. A randomised trial comparing open Burch colposuspension using sutures with laparoscopic colposuspension using mesh and staples in women with stress urinary incontinence. Bjog. Sep. 2004;111(9):974-81. [pmid: 15327613].
670 Ross J. Two techniques of laparoscopic Burch repair for stress incontinence: a prospective, randomized study. J Am Assoc Gynecol Laparosc. May. 1996;3(3):351-7. [pmid: 9050655].
671 Klarskov P, Belving D, Bischoff N, et al. Pelvic floor exercise versus surgery for female urinary stress incontinence. Urol Int. 1986;41(2):129-32. [pmid: 3727190].
672 Albo ME, Richter HE, Brubaker L, et al. Burch colposuspension versus fascial sling to reduce urinary stress incontinence. N Engl J Med. May 24. 2007;356(21):2143-55. [pmid: 17517855].
673 Carey MP, Goh JT, Rosamilia A, et al. Laparoscopic versus open Burch colposuspension: a randomised controlled trial. BJOG. Sep. 2006;113(9):999-1006. [pmid: 16956331].
674 Peeters KC, van de Velde CJ, Leer JW, et al. Late side effects of short-course preoperative radiotherapy combined with total mesorectal excision for rectal cancer: increased bowel dysfunction in irradiated patients—a Dutch colorectal cancer group study. J Clin Oncol. Sep 1. 2005;23(25):6199-206. [pmid: 16135487].
675 Pollack J, Holm T, Cedermark B, et al. Late adverse effects of short-course preoperative radiotherapy in rectal cancer. Br J Surg. Dec. 2006;93(12):1519-25. [pmid: 17054311].
676 Little DJ, Kuban DA, Levy LB, et al. Quality-of-life questionnaire results 2 and 3 years after radiotherapy for prostate cancer in a randomized dose-escalation study. Urology. Oct. 2003;62(4):707-13. [pmid: 14550448].
677 Srougi M, Paranhos M, Leite KM, et al. The influence of bladder neck mucosal eversion and early urinary extravasation on patient outcome after radical retropubic prostatectomy: a prospective controlled trial. BJU Int. Apr. 2005;95(6):757-60. [pmid: 15794777].
678 Wasson JH, Reda DJ, Bruskewitz RC, et al. A comparison of transurethral surgery with watchful waiting for moderate symptoms of benign prostatic hyperplasia. The Veterans Affairs Cooperative Study Group on Transurethral Resection of the Prostate. N Engl J Med. Jan 12. 1995;332(2):75-9. [pmid: 7527493].
679 Van Cangh PJ, Richard F, Lorge F, et al. Adjuvant radiation therapy does not cause urinary incontinence after radical prostatectomy: results of a prospective randomized study. J Urol. Jan. 1998;159(1):164-6. [pmid: 9400462].
680 Srougi M, Nesrallah LJ, Kauffmann JR, et al. Urinary continence and pathological outcome after bladder neck preservation during radical retropubic prostatectomy: a randomized prospective trial. J Urol. Mar. 2001;165(3):815-8. [pmid: 11176476].
681 Ghaly M, Wallner K, Merrick G, et al. The effect of supplemental beam radiation on prostate brachytherapy-related morbidity: morbidity outcomes from two prospective randomized multicenter trials. Int J Radiat Oncol Biol Phys. Apr 1. 2003;55(5):1288-93. [pmid: 12654439].
682 Imamoglu MA, Tuygun C, Bakirtas H, et al. The comparison of artificial urinary sphincter implantation and endourethral macroplastique injection for the treatment of postprostatectomy incontinence. Eur Urol. Feb. 2005;47(2):209-13. [pmid: 15661416].
683 Deliveliotis C, Delis A, Papatsoris A, et al. Local steroid application during nerve-sparing radical retropubic prostatectomy. BJU Int. Sep. 2005;96(4):533-5. [pmid: 16104905].
684 Parsons JK, Marschke P, Maples P, et al. Effect of methylprednisolone on return of sexual function after nerve-sparing radical retropubic prostatectomy. Urology. Nov. 2004;64(5):987-90. [pmid: 15533491].
685 Akakura K, Isaka S, Akimoto S, et al. Long-term results of a randomized trial for the treatment of Stages B2 and C prostate cancer: radical prostatectomy versus external beam radiation therapy with a common endocrine therapy in both modalities. Urology. Aug. 1999;54(2):313-8. [pmid: 10443731].
686 Fransson P, Damber JE, Tomic R, et al. Quality of life and symptoms in a randomized trial of radiotherapy versus deferred treatment of localized prostate carcinoma. Cancer. Dec 15. 2001;92(12):3111-9. [pmid: 11753990].
687 Gupta NP, Doddamani D, Aron M, et al. Vapor resection: a good alternative to standard loop resection in the management of prostates >40 cc. J Endourol. Dec. 2002;16(10):767-71. [pmid: 12542882].
688 Gallucci M, Puppo P, Perachino M, et al. Transurethral electrovaporization of the prostate vs. transurethral resection. Results of a multicentric, randomized clinical study on 150 patients. Eur Urol. 1998;33(4):359-64. [pmid: 9612677].
689 Wilson LC, Gilling PJ, Williams A, et al. A randomised trial comparing holmium laser enucleation versus transurethral resection in the treatment of prostates larger than 40 grams: results at 2 years. Eur Urol. Sep. 2006;50(3):569-73. [pmid: 16704894].
690 Steineck G, Helgesen F, Adolfsson J, et al. Quality of life after radical prostatectomy or watchful waiting. N Engl J Med. Sep 12. 2002;347(11):790-6. [pmid: 12226149].
691 Goldstein SR, Johnson S, Watts NB, et al. Incidence of urinary incontinence in postmenopausal women treated with raloxifene or estrogen. Menopause. Mar. 2005;12(2):160-4. [pmid: 15772563].
692 Vardy MD, Lindsay R, Scotti RJ, et al. Short-term urogenital effects of raloxifene, tamoxifen, and estrogen. Am J Obstet Gynecol. Jul. 2003;189(1):81-8. [pmid: 12861143].
693 Warming L, Christoffersen C, Riis BJ, et al. Adverse effects of a SERM (Levormeloxifene). Safety parameters and bone mineral density 12 months after treatment withdrawal. Maturitas. Mar 28. 2003;44(3):189-99. [pmid: 12648882].
694 Steinauer JE, Waetjen LE, Vittinghoff E, et al. Postmenopausal hormone therapy: does it cause incontinence?. Obstet Gynecol. Nov. 2005;106(5 Pt 1):940-5. [pmid: 16260510]. [pmcid: 1557396].
695 Hendrix SL, Cochrane BB, Nygaard IE, et al. Effects of estrogen with and without progestin on urinary incontinence. Jama. Feb 23. 2005;293(8):935-48. [pmid: 15728164].
696 Vestergaard P, Hermann AP, Stilgren L, et al. Effects of 5 years of hormonal replacement therapy on menopausal symptoms and blood pressure-a randomised controlled study. Maturitas. Oct 20. 2003;46(2):123-32. [pmid: 14559383].
697 Goldstein SR, Nanavati N. Adverse events that are associated with the selective estrogen receptor modulator levormeloxifene in an aborted phase III osteoporosis treatment study. Am J Obstet Gynecol. Sep. 2002;187(3):521-7. [pmid: 12237621].
698 Kok AL, Burger CW, van de Weijer PH, et al. Micturition complaints in postmenopausal women treated with continuously combined hormone replacement therapy: a prospective study. Maturitas. Jan 4. 1999;31(2):143-9. [pmid: 10227008].
699 Long CY, Liu CM, Hsu SC, et al. A randomized comparative study of the effects of oral and topical estrogen therapy on the lower urinary tract of hysterectomized postmenopausal women. Fertil Steril. Jan. 2006;85(1):155-60. [pmid: 16412747].
700 Jackson S, James M, Abrams P. The effect of oestradiol on vaginal collagen metabolism in postmenopausal women with genuine stress incontinence. Bjog. Mar. 2002;109(3):339-44. [pmid: 11950190].
701 Fantl JA, Bump RC, Robinson D, et al. Efficacy of estrogen supplementation in the treatment of urinary incontinence. The Continence Program for Women Research Group. Obstet Gynecol. Nov. 1996;88(5):745-9. [pmid: 8885906].
702 Jackson S, Shepherd A, Brookes S, et al. The effect of oestrogen supplementation on post-menopausal urinary stress incontinence: a double-blind placebo-controlled trial. Br J Obstet Gynaecol. Jul. 1999;106(7):711-8. [pmid: 10428529].
703 Ishiko O, Hirai K, Sumi T, et al. Hormone replacement therapy plus pelvic floor muscle exercise for postmenopausal stress incontinence. A randomized, controlled trial. J Reprod Med. Mar. 2001;46(3):213-20. [pmid: 11304861].
704 Rufford J, Hextall A, Cardozo L, et al. A double-blind placebo-controlled trial on the effects of 25 mg estradiol implants on the urge syndrome in postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):78-83. [pmid: 12851747].
705 Ahlstrom K, Sandahl B, Sjoberg B, et al. Effect of combined treatment with phenylpropanolamine and estriol, compared with estriol treatment alone, in postmenopausal women with stress urinary incontinence. Gynecol Obstet Invest. 1990;30(1):37-43. [pmid: 2227611].
706 Cardozo L, Rekers H, Tapp A, et al. Oestriol in the treatment of postmenopausal urgency: a multicentre study. Maturitas. Dec. 1993;18(1):47-53. [pmid: 8107615].
707 Kinn AC, Lindskog M. Estrogens and phenylpropanolamine in combination for stress urinary incontinence in postmenopausal women. Urology. Sep. 1988;32(3):273-80. [pmid: 3046105].
708 Wilson PD, Faragher B, Butler B, et al. Treatment with oral piperazine oestrone sulphate for genuine stress incontinence in postmenopausal women. Br J Obstet Gynaecol. Jun. 1987;94(6):568-74. [pmid: 3113475].
709 Waetjen LE, Brown JS, Modelska K, et al. Effect of raloxifene on urinary incontinence: a randomized controlled trial. Obstet Gynecol. Feb. 2004;103(2):261-6. [pmid: 14754693].
710 Grady D, Brown JS, Vittinghoff E, et al. Postmenopausal hormones and incontinence: the Heart and Estrogen/Progestin Replacement Study. Obstet Gynecol. Jan. 2001;97(1):116-20. [pmid: 11152919].
711 von Holst T, Salbach B. Efficacy and tolerability of a new 7-day transdermal estradiol patch versus placebo in hysterectomized women with postmenopausal complaints. Maturitas. Feb 15. 2000;34(2):143-53. [pmid: 10714909].
712 Waetjen LE, Brown JS, Vittinghoff E, et al. The effect of ultralow-dose transdermal estradiol on urinary incontinence in postmenopausal women. Obstet Gynecol. Nov. 2005;106(5 Pt 1):946-52. [pmid: 16260511]. [pmcid: 1557395].
713 Holtedahl K, Verelst M, Schiefloe A. A population based, randomized, controlled trial of conservative treatment for urinary incontinence in women. Acta Obstet Gynecol Scand. Jul. 1998;77(6):671-7. [pmid: 9688247].
714 Dessole S, Rubattu G, Ambrosini G, et al. Efficacy of low-dose intravaginal estriol on urogenital aging in postmenopausal women. Menopause. Jan–Feb. 2004;11(1):49-56. [pmid: 14716182].
715 Mikkelsen AL, Felding C, Clausen HV. Clinical effects of preoperative oestradiol treatment before vaginal repair operation. A double-blind, randomized trial. Gynecol Obstet Invest. 1995;40(2):125-8. [pmid: 8575690].
716 Akhila V, Pratapkumar. A comparison of transdermal and oral HRT for menopausal symptom control. Int J Fertil Womens Med. Mar–Apr. 2006;51(2):64-9. [pmid: 16881381].
717 Lose G, Englev E. Oestradiol-releasing vaginal ring versus oestriol vaginal pessaries in the treatment of bothersome lower urinary tract symptoms. Bjog. Aug. 2000;107(8):1029-34. [pmid: 10955437].
718 Chompootaweep S, Nunthapisud P, Trivijitsilp P, et al. The use of two estrogen preparations (a combined contraceptive pill versus conjugated estrogen cream) intravaginally to treat urogenital symptoms in postmenopausal Thai women: a comparative study. Clin Pharmacol Ther. Aug. 1998;64(2):204-10. [pmid: 9728901].
719 Blom W, Sommers DK. The effects of an estradiol transdermal therapeutic system, alone and in combination with naproxen, on urge incontinence in elderly women: a pilot study: Trials in special populations. Current therapeutic research. 1995;56(10):1100-4.
720 Chassagne P, Jego A, Gloc P, et al. Does treatment of constipation improve faecal incontinence in institutionalized elderly patients?. Age Ageing. Mar. 2000;29(2):159-64. [pmid: 10791451].
721 Harari D, Norton C, Lockwood L, et al. Treatment of constipation and fecal incontinence in stroke patients: randomized controlled trial. Stroke. Nov. 2004;35(11):2549-55. [pmid: 15486330].
722 Bliss DZ, Jung HJ, Savik K, et al. Supplementation with dietary fiber improves fecal incontinence. Nurs Res. Jul–Aug. 2001;50(4):203-13. [pmid: 11480529].
723 Fynes MM, Marshall K, Cassidy M, et al. A prospective, randomized study comparing the effect of augmented biofeedback with sensory biofeedback alone on fecal incontinence after obstetric trauma. Dis Colon Rectum. Jun. 1999;42(6):753-8. discussion 8–61. [pmid: 10378599].
724 Ilnyckyj A, Fachnie E, Tougas G. A randomized-controlled trial comparing an educational intervention alone vs education and biofeedback in the management of faecal incontinence in women. Neurogastroenterol Motil. Feb. 2005;17(1):58-63. [pmid: 15670265].
725 Byrne CM, Pager CK, Rex J, et al. Assessment of quality of life in the treatment of patients with neuropathic fecal incontinence. Dis Colon Rectum. Nov. 2002;45(11):1431-6. [pmid: 12432287].
726 Byrne CM, Solomon MJ, Rex J, et al. Telephone vs. face-to-face biofeedback for fecal incontinence: comparison of two techniques in 239 patients. Dis Colon Rectum. Dec. 2005;48(12):2281-8. [pmid: 16258709].
727 Solomon MJ, Pager CK, Rex J, et al. Randomized, controlled trial of biofeedback with anal manometry, transanal ultrasound, or pelvic floor retraining with digital guidance alone in the treatment of mild to moderate fecal incontinence. Dis Colon Rectum. Jun. 2003;46(6):703-10. [pmid: 12794569].
728 Pager CK, Solomon MJ, Rex J, et al. Long-term outcomes of pelvic floor exercise and biofeedback treatment for patients with fecal incontinence. Dis Colon Rectum. Aug. 2002;45(8):997-1003. [pmid: 12195181].
729 Norton C, Chelvanayagam S, Wilson-Barnett J, et al. Randomized controlled trial of biofeedback for fecal incontinence. Gastroenterology. Nov. 2003;125(5):1320-9. [pmid: 14598248].
730 Jorge JM, Wexner SD, Morgado PJ Jr, et al. Optimization of sphincter function after the ileoanal reservoir procedure. A prospective, randomized trial. Dis Colon Rectum. May. 1994;37(5):419-23. [pmid: 8181400].
731 Miner PB, Donnelly TC, Read NW. Investigation of mode of action of biofeedback in treatment of fecal incontinence. Dig Dis Sci. Oct. 1990;35(10):1291-8. [pmid: 2209296].
732 Norton C, Gibbs A, Kamm MA. Randomized, controlled trial of anal electrical stimulation for fecal incontinence. Dis Colon Rectum. Feb. 2006;49(2):190-6. [pmid: 16362803].
733 Leroi AM, Parc Y, Lehur PA, et al. Efficacy of sacral nerve stimulation for fecal incontinence: results of a multicenter double-blind crossover study. Ann Surg. Nov. 2005;242(5):662-9. [pmid: 16244539]. [pmcid: 1409867].
734 Chang HS, Myung SJ, Yang SK, et al. Effect of electrical stimulation in constipated patients with impaired rectal sensation. Int J Colorectal Dis. Sep. 2003;18(5):433-8. [pmid: 12677456].
735 Healy CF, Brannigan AE, Connolly EM, et al. The effects of low-frequency endo-anal electrical stimulation on faecal incontinence: a prospective study. Int J Colorectal Dis. Dec. 2006;21(8):802-6. [pmid: 16544149].
736 Mahony RT, Malone PA, Nalty J, et al. Randomized clinical trial of intra-anal electromyographic biofeedback physiotherapy with intra-anal electromyographic biofeedback augmented with electrical stimulation of the anal sphincter in the early treatment of postpartum fecal incontinence. Am J Obstet Gynecol. Sep. 2004;191(3):885-90. [pmid: 15467559].
737 Ho KS, Ho YH. Randomized clinical trial comparing oral nifedipine with lateral anal sphincterotomy and tailored sphincterotomy in the treatment of chronic anal fissure. Br J Surg. Apr. 2005;92(4):403-8. [pmid: 15739214].
738 De Nardi P, Ortolano E, Radaelli G, et al. Comparison of glycerine trinitrate and botulinum toxin-a for the treatment of chronic anal fissure: long-term results. Dis Colon Rectum. Apr. 2006;49(4):427-32. [pmid: 16456637].
739 Ron Y, Avni Y, Lukovetski A, et al. Botulinum toxin type-A in therapy of patients with anismus. Dis Colon Rectum. Dec. 2001;44(12):1821-6. [pmid: 11742168].
740 Mentes BB, Irkorucu O, Akin M, et al. Comparison of botulinum toxin injection and lateral internal sphincterotomy for the treatment of chronic anal fissure. Dis Colon Rectum. Feb. 2003;46(2):232-7. [pmid: 12576897].
741 Iswariah H, Stephens J, Rieger N, et al. Randomized prospective controlled trial of lateral internal sphincterotomy versus injection of botulinum toxin for the treatment of idiopathic fissure in ano. ANZ J Surg. Jul. 2005;75(7):553-5. [pmid: 15972045].
742 Brisinda G, Maria G, Bentivoglio AR, et al. A comparison of injections of botulinum toxin and topical nitroglycerin ointment for the treatment of chronic anal fissure. N Engl J Med. Jul 8. 1999;341(2):65-9. [pmid: 10395629].
743 Siproudhis L, Sebille V, Pigot F, et al. Lack of effficacy of botulinum toxin in chronic anal fissure. Aliment Pharmacol Ther. Sep 1. 2003;18(5):515-24. [pmid: 12950424].
744 Hallgren T, Fasth S, Delbro DS, et al. Loperamide improves anal sphincter function and continence after restorative proctocolectomy. Dig Dis Sci. Dec. 1994;39(12):2612-8. [pmid: 7995187].
745 Sun WM, Read NW, Verlinden M. Effects of loperamide oxide on gastrointestinal transit time and anorectal function in patients with chronic diarrhoea and faecal incontinence. Scand J Gastroenterol. Jan. 1997;32(1):34-8. [pmid: 9018764].
746 Kneebone A, Mameghan H, Bolin T, et al. Effect of oral sucralfate on late rectal injury associated with radiotherapy for prostate cancer: A double-blind, randomized trial. Int J Radiat Oncol Biol Phys. Nov 15. 2004;60(4):1088-97. [pmid: 15519779].
747 Carapeti EA, Kamm MA, Phillips RK. Randomized controlled trial of topical phenylephrine in the treatment of faecal incontinence. Br J Surg. Jan. 2000;87(1):38-42. [pmid: 10606908].
748 Carapeti EA, Kamm MA, Nicholls RJ, et al. Randomized, controlled trial of topical phenylephrine for fecal incontinence in patients after ileoanal pouch construction. Dis Colon Rectum. Aug. 2000;43(8):1059-63. [pmid: 10950003].
749 Nessim A, Wexner SD, Agachan F, et al. Is bowel confinement necessary after anorectal reconstructive surgery? A prospective, randomized, surgeon-blinded trial. Dis Colon Rectum. Jan. 1999;42(1):16-23. [pmid: 10211515].
750 Tankova L, Yoncheva K, Muhtarov M, et al. Topical mononitrate treatment in patients with anal fissure. Aliment Pharmacol Ther. Jan. 2002;16(1):101-3. [pmid: 11856083].
751 Fernando RJ, Sultan AH, Kettle C, et al. Repair techniques for obstetric anal sphincter injuries: a randomized controlled trial. Obstet Gynecol. Jun. 2006;107(6):1261-8. [pmid: 16738150].
752 Williams A, Adams EJ, Tincello DG, et al. How to repair an anal sphincter injury after vaginal delivery: results of a randomised controlled trial. Bjog. Feb. 2006;113(2):201-7. [pmid: 16411999].
753 Tjandra JJ, Han WR, Goh J, et al. Direct repair vs. overlapping sphincter repair: a randomized, controlled trial. Dis Colon Rectum. Jul. 2003;46(7):937-42. discussion 42–3. [pmid: 12847369].
754 Fitzpatrick M, Behan M, O'Connell PR, et al. A randomized clinical trial comparing primary overlap with approximation repair of third-degree obstetric tears. Am J Obstet Gynecol. Nov. 2000;183(5):1220-4. [pmid: 11084569].
755 Fitzpatrick M, Harkin R, McQuillan K, et al. A randomised clinical trial comparing the effects of delayed versus immediate pushing with epidural analgesia on mode of delivery and faecal continence. Bjog. Dec. 2002;109(12):1359-65. [pmid: 12504971].
756 Fitzpatrick M, Behan M, O'Connell PR, et al. Randomised clinical trial to assess anal sphincter function following forceps or vacuum assisted vaginal delivery. Bjog. Apr. 2003;110(4):424-9. [pmid: 12699806].
757 Sultan AH, Johanson RB, Carter JE. Occult anal sphincter trauma following randomized forceps and vacuum delivery. Int J Gynaecol Obstet. May. 1998;61(2):113-9. [pmid: 9639214].
758 Faltin DL, Boulvain M, Floris LA, et al. Diagnosis of anal sphincter tears to prevent fecal incontinence: a randomized controlled trial. Obstet Gynecol. Jul. 2005;106(1):6-13. [pmid: 15994610].
759 Deen KI, Grant E, Billingham C, et al. Abdominal resection rectopexy with pelvic floor repair versus perineal rectosigmoidectomy and pelvic floor repair for full-thickness rectal prolapse. Br J Surg. Feb. 1994;81(2):302-4. [pmid: 8156369].
760 Sayfan J, Pinho M, Alexander-Williams J, et al. Sutured posterior abdominal rectopexy with sigmoidectomy compared with Marlex rectopexy for rectal prolapse. Br J Surg. Feb. 1990;77(2):143-5. [pmid: 2317672].
761 Yoshioka K, Ogunbiyi OA, Keighley MR. A pilot study of total pelvic floor repair or gluteus maximus transposition for postobstetric neuropathic fecal incontinence. Dis Colon Rectum. Feb. 1999;42(2):252-7. [pmid: 10211504].
762 Deen KI, Oya M, Ortiz J, et al. Randomized trial comparing three forms of pelvic floor repair for neuropathic faecal incontinence. Br J Surg. Jun. 1993;80(6):794-8. [pmid: 8330179].
763 Davis KJ, Kumar D, Poloniecki J. Adjuvant biofeedback following anal sphincter repair: a randomized study. Aliment Pharmacol Ther. Sep 1. 2004;20(5):539-49. [pmid: 15339325].
764 Deen KI, Kumar D, Williams JG, et al. Randomized trial of internal anal sphincter plication with pelvic floor repair for neuropathic fecal incontinence. Dis Colon Rectum. Jan. 1995;38(1):14-8. [pmid: 7813338].
765 van Tets WF, Kuijpers JH. Pelvic floor procedures produce no consistent changes in anatomy or physiology. Dis Colon Rectum. Mar. 1998;41(3):365-9. [pmid: 9514434].
766 Peeters ST, Lebesque JV, Heemsbergen WD, et al. Localized volume effects for late rectal and anal toxicity after radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. Mar 15. 2006;64(4):1151-61. [pmid: 16414208].
767 Christensen P, Bazzocchi G, Coggrave M, et al. A randomized, controlled trial of transanal irrigation versus conservative bowel management in spinal cord-injured patients. Gastroenterology. Sep. 2006;131(3):738-47. [pmid: 16952543].
768 Hetzer FH, Demartines N, Handschin AE, et al. Stapled vs excision hemorrhoidectomy: long-term results of a prospective randomized trial. Arch Surg. Mar. 2002;137(3):337-40. [pmid: 11888463].
769 Konsten J, Baeten CG. Hemorrhoidectomy vs. Lord's method: 17-year follow-up of a prospective, randomized trial. Dis Colon Rectum. Apr. 2000;43(4):503-6. [pmid: 10789746].
770 Jayne DG, Botterill I, Ambrose NS, et al. Randomized clinical trial of Ligasure versus conventional diathermy for day-case haemorrhoidectomy. Br J Surg. Apr. 2002;89(4):428-32. [pmid: 11952582].
771 Galizia G, Lieto E, Castellano P, et al. Lateral internal sphincterotomy together with haemorrhoidectomy for treatment of haemorrhoids: a randomised prospective study. Eur J Surg. Mar. 2000;166(3):223-8. [pmid: 10755337].
772 Lawes DA, Palazzo FF, Francis DL, et al. One year follow up of a randomized trial comparing Ligasure with open haemorrhoidectomy. Colorectal Dis. Jul. 2004;6(4):233-5. [pmid: 15206964].
773 Filingeri V, Gravante G, Baldessari E, et al. Prospective randomized trial of submucosal hemorrhoidectomy with radiofrequency bistoury vs. conventional Parks' operation. Tech Coloproctol. Mar. 2004;8(1):31-6. [pmid: 15057587].
774 Johannsson HO, Pahlman L, Graf W. Randomized clinical trial of the effects on anal function of Milligan-Morgan versus Ferguson haemorrhoidectomy. Br J Surg. Oct. 2006;93(10):1208-14. [pmid: 16952213].
775 Khan S, Pawlak SE, Eggenberger JC, et al. Surgical treatment of hemorrhoids: prospective, randomized trial comparing closed excisional hemorrhoidectomy and the Harmonic Scalpel technique of excisional hemorrhoidectomy. Dis Colon Rectum. Jun. 2001;44(6):845-9. [pmid: 11391146].
776 van Tets WF, Kuijpers JH, Tran K, et al. Influence of Parks' anal retractor on anal sphincter pressures. Dis Colon Rectum. Sep. 1997;40(9):1042-5. [pmid: 9293932].
777 Ho YH, Cheong WK, Tsang C, et al. Stapled hemorrhoidectomy—cost and effectiveness. Randomized, controlled trial including incontinence scoring, anorectal manometry, and endoanal ultrasound assessments at up to three months. Dis Colon Rectum. Dec. 2000;43(12):1666-75. [pmid: 11156449].
778 Schouten WR, van Vroonhoven TJ. Treatment of anorectal abscess with or without primary fistulectomy. Results of a prospective randomized trial. Dis Colon Rectum. Jan. 1991;34(1):60-3. [pmid: 1991422].
779 Singer M, Cintron J, Nelson R, et al. Treatment of fistulas-in-ano with fibrin sealant in combination with intra-adhesive antibiotics and/or surgical closure of the internal fistula opening. Dis Colon Rectum. Apr. 2005;48(4):799-808. [pmid: 15785883].
780 Libertiny G, Knight JS, Farouk R. Randomised trial of topical 0.2% glyceryl trinitrate and lateral internal sphincterotomy for the treatment of patients with chronic anal fissure: long-term follow-up. Eur J Surg. 2002;168(7):418-21. [pmid: 12463433].
781 Mishra R, Thomas S, Maan MS, et al. Topical nitroglycerin versus lateral internal sphincterotomy for chronic anal fissure: prospective, randomized trial. ANZ J Surg. Dec. 2005;75(12):1032-5. [pmid: 16398803].
782 Oettle GJ. Glyceryl trinitrate vs. sphincterotomy for treatment of chronic fissure-in-ano: a randomized, controlled trial. Dis Colon Rectum. Nov. 1997;40(11):1318-20. [pmid: 9369106].
783 Richard CS, Gregoire R, Plewes EA, et al. Internal sphincterotomy is superior to topical nitroglycerin in the treatment of chronic anal fissure: results of a randomized, controlled trial by the Canadian Colorectal Surgical Trials Group. Dis Colon Rectum. Aug. 2000;43(8):1048-57. discussion 57–8. [pmid: 10950002].
784 Evans J, Luck A, Hewett P. Glyceryl trinitrate vs. lateral sphincterotomy for chronic anal fissure: prospective, randomized trial. Dis Colon Rectum. Jan. 2001;44(1):93-7. [pmid: 11805569].
785 Zimmerman DD, Gosselink MP, Hop WC, et al. Impact of two different types of anal retractor on fecal continence after fistula repair: a prospective, randomized, clinical trial. Dis Colon Rectum. Dec. 2003;46(12):1674-9. [pmid: 14668594].
786 Ho KS, Ho YH. Controlled, randomized trial of island flap anoplasty for treatment of trans-sphincteric fistula-in-ano: early results. Tech Coloproctol. Jul. 2005;9(2):166-8. [pmid: 16007352].
787 Dahlberg M, Glimelius B, Graf W, et al. Preoperative irradiation affects functional results after surgery for rectal cancer: results from a randomized study. Dis Colon Rectum. May. 1998;41(5):543-9. discussion 9–51. [pmid: 9593234].
788 Allgayer H, Dietrich CF, Rohde W, et al. Prospective comparison of short- and long-term effects of pelvic floor exercise/biofeedback training in patients with fecal incontinence after surgery plus irradiation versus surgery alone for colorectal cancer: clinical, functional and endoscopic/endosonographic findings. Scand J Gastroenterol. Oct. 2005;40(10):1168-75. [pmid: 16165701].
789 Lundby L, Krogh K, Jensen VJ, et al. Long-term anorectal dysfunction after postoperative radiotherapy for rectal cancer. Dis Colon Rectum. Jul. 2005;48(7):1343-9. discussion 9–52; author reply 52. [pmid: 15933797].
790 Luukkonen P, Mikkonen U, Jarvinen H. Abdominal rectopexy with sigmoidectomy vs. rectopexy alone for rectal prolapse: a prospective, randomized study. Int J Colorectal Dis. Dec. 1992;7(4):219-22. [pmid: 1338091].
791 Racalbuto A, Aliotta I, Corsaro G, et al. Hemorrhoidal stapler prolapsectomy vs. Milligan-Morgan hemorrhoidectomy: a long-term randomized trial. Int J Colorectal Dis. May. 2004;19(3):239-44. [pmid: 14605834].
792 Novell JR, Osborne MJ, Winslet MC, et al. Prospective randomized trial of Ivalon sponge versus sutured rectopexy for full-thickness rectal prolapse. Br J Surg. Jun. 1994;81(6):904-6. [pmid: 8044618].
793 Solomon MJ, Young CJ, Eyers AA, et al. Randomized clinical trial of laparoscopic versus open abdominal rectopexy for rectal prolapse. Br J Surg. Jan. 2002;89(1):35-9. [pmid: 11851660].
794 Galili Y, Rabau M. Comparison of polyglycolic acid and polypropylene mesh for rectopexy in the treatment of rectal prolapse. Eur J Surg. Jun. 1997;163(6):445-8. [pmid: 9231856].
795 Boccasanta P, Venturi M, Barbieri S, et al. Impact of new technologies on the clinical and functional outcome of Altemeier's procedure: a randomized, controlled trial. Dis Colon Rectum. May. 2006;49(5):652-60. [pmid: 16575620].
796 Boccasanta P, Rosati R, Venturi M, et al. Comparison of laparoscopic rectopexy with open technique in the treatment of complete rectal prolapse: clinical and functional results. Surg Laparosc Endosc. Dec. 1998;8(6):460-5. [pmid: 9864116].
797 Wiley M, Day P, Rieger N, et al. Open vs. closed lateral internal sphincterotomy for idiopathic fissure-in-ano: a prospective, randomized, controlled trial. Dis Colon Rectum. Jun. 2004;47(6):847-52. [pmid: 15129311].
798 Parellada C. Randomized, prospective trial comparing 0.2 percent isosorbide dinitrate ointment with sphincterotomy in treatment of chronic anal fissure: a two-year follow-up. Dis Colon Rectum. Apr. 2004;47(4):437-43. [pmid: 14994114].
799 Wong WD, Congliosi SM, Spencer MP, et al. The safety and efficacy of the artificial bowel sphincter for fecal incontinence: results from a multicenter cohort study. Dis Colon Rectum. Sep. 2002;45(9):1139-53. [pmid: 12352228].
800 Arroyo Sebastian A, Perez Vicente F, Miranda Tauler E, et al. Surgical (close lateral internal sphincterotomy) versus chemical (botulinum toxin) sphincterotomy as treatment of chronic anal fissure. Med Clin (Barc). Apr 23. 2005;124(15):573-5. [pmid: 15860170].
801 Zbar AP, Ramesh J, Beer-Gabel M, et al. Conventional cutting vs. internal anal sphincter-preserving seton for high trans-sphincteric fistula: a prospective randomized manometric and clinical trial. Tech Coloproctol. Jul. 2003;7(2):89-94. [pmid: 14605927].
802 Osterberg A, Edebol Eeg-Olofsson K, Hallden M, et al. Randomized clinical trial comparing conservative and surgical treatment of neurogenic faecal incontinence. Br J Surg. Sep. 2004;91(9):1131-7. [pmid: 15449263].
803 Tjandra JJ, Lim JF, Hiscock R, et al. Injectable silicone biomaterial for fecal incontinence caused by internal anal sphincter dysfunction is effective. Dis Colon Rectum. Dec. 2004;47(12):2138-46. [pmid: 15657666].
804 O'Brien PE, Dixon JB, Skinner S, et al. A prospective, randomized, controlled clinical trial of placement of the artificial bowel sphincter (Acticon Neosphincter) for the control of fecal incontinence. Dis Colon Rectum. Nov. 2004;47(11):1852-60. [pmid: 15622577].
805 Seow-Choen F, Goh HS. Prospective randomized trial comparing J colonic pouch-anal anastomosis and straight coloanal reconstruction. Br J Surg. May. 1995;82(5):608-10. [pmid: 7613927].
806 Ho YH, Seow-Choen F, Tan M. Colonic J-pouch function at six months versus straight coloanal anastomosis at two years: randomized controlled trial. World J Surg. Jul. 2001;25(7):876-81. [pmid: 11572027].
807 Soliani P, Carbognani P, Piccolo P, et al. Colostomy plug devices: a possible new approach to the problem of incontinence. Dis Colon Rectum. Oct. 1992;35(10):969-74. [pmid: 1395985].
808 Hallbook O, Pahlman L, Krog M, et al. Randomized comparison of straight and colonic J pouch anastomosis after low anterior resection. Ann Surg. Jul. 1996;224(1):58-65. [pmid: 8678619]. [pmcid: 1235247].
809 Ho YH, Brown S, Heah SM, et al. Comparison of J-pouch and coloplasty pouch for low rectal cancers: a randomized, controlled trial investigating functional results and comparative anastomotic leak rates. Ann Surg. Jul. 2002;236(1):49-55. [pmid: 12131085]. [pmcid: 1422548].
810 Machado M, Nygren J, Goldman S, et al. Functional and physiologic assessment of the colonic reservoir or side-to-end anastomosis after low anterior resection for rectal cancer: a two-year follow-up. Dis Colon Rectum. Jan. 2005;48(1):29-36. [pmid: 15690654].
811 Laurent A, Parc Y, McNamara D, et al. Colonic J-pouch-anal anastomosis for rectal cancer: a prospective, randomized study comparing handsewn vs. stapled anastomosis. Dis Colon Rectum. Apr. 2005;48(4):729-34. [pmid: 15719189].
812 Lazorthes F, Gamagami R, Chiotasso P, et al. Prospective, randomized study comparing clinical results between small and large colonic J-pouch following coloanal anastomosis. Dis Colon Rectum. Dec. 1997;40(12):1409-13. [pmid: 9407976].
813 McKee RF, Lauder JC, Poon FW, et al. A prospective randomized study of abdominal rectopexy with and without sigmoidectomy in rectal prolapse. Surg Gynecol Obstet. Feb. 1992;174(2):145-8. [pmid: 1734574].
814 Furst A, Suttner S, Agha A, et al. Colonic J-pouch vs. coloplasty following resection of distal rectal cancer: early results of a prospective, randomized, pilot study. Dis Colon Rectum. Sep. 2003;46(9):1161-6. [pmid: 12972958].
815 Hasegawa H, Yoshioka K, Keighley MR. Randomized trial of fecal diversion for sphincter repair. Dis Colon Rectum. Jul. 2000;43(7):961-4. discussion 4–5. [pmid: 10910243].
816 Sailer M, Fuchs KH, Fein M, et al. Randomized clinical trial comparing quality of life after straight and pouch coloanal reconstruction. Br J Surg. Sep. 2002;89(9):1108-17. [pmid: 12190675].
817 Ho YH, Yu S, Ang ES, et al. Small colonic J-pouch improves colonic retention of liquids—randomized, controlled trial with scintigraphy. Dis Colon Rectum. Jan. 2002;45(1):76-82. [pmid: 11786768].
818 Furst A, Burghofer K, Hutzel L, et al. Neorectal reservoir is not the functional principle of the colonic J-pouch: the volume of a short colonic J-pouch does not differ from a straight coloanal anastomosis. Dis Colon Rectum. May. 2002;45(5):660-7. [pmid: 12004217].
819 Jiang JK, Yang SH, Lin JK. Transabdominal anastomosis after low anterior resection: A prospective, randomized, controlled trial comparing long-term results between side-to-end anastomosis and colonic J-pouch. Dis Colon Rectum. Nov. 2005;48(11):2100-8. discussion 8–10. [pmid: 16132480].
820 Reilly WT, Pemberton JH, Wolff BG, et al. Randomized prospective trial comparing ileal pouch-anal anastomosis performed by excising the anal mucosa to ileal pouch-anal anastomosis performed by preserving the anal mucosa. Ann Surg. Jun. 1997;225(6):666-76. discussion 76–7. [pmid: 9230807]. [pmcid: 1190866].
821 Johnston D, Williamson ME, Lewis WG, et al. Prospective controlled trial of duplicated (J) versus quadruplicated (W) pelvic ileal reservoirs in restorative proctocolectomy for ulcerative colitis. Gut. Aug. 1996;39(2):242-7. [pmid: 8991863]. [pmcid: 1383306].
822 Selvaggi F, Giuliani A, Gallo C, et al. Randomized, controlled trial to compare the J-pouch and W-pouch configurations for ulcerative colitis in the maturation period. Dis Colon Rectum. May. 2000;43(5):615-20. [pmid: 10826420].
823 Oresland T, Fasth S, Hulten L, et al. Does balloon dilatation and anal sphincter training improve ileoanal-pouch function?. Int J Colorectal Dis. Aug. 1988;3(3):153-7. [pmid: 3183476].
824 Hahnloser D, Pemberton JH, Wolff BG, et al. Results at up to 20 years after ileal pouch-anal anastomosis for chronic ulcerative colitis. Br J Surg. Mar. 2007;94(3):333-40. [pmid: 17225210].
825 Park JG, Lee MR, Lim SB, et al. Colonic J-pouch anal anastomosis after ultralow anterior resection with upper sphincter excision for low-lying rectal cancer. World J Gastroenterol. May 7. 2005;11(17):2570-3. [pmid: 15849813].
826 De Muylder X, Claes H, Neven P, et al. Usefulness of urodynamic investigations in female incontinence. Eur J Obstet Gynecol Reprod Biol. May 13. 1992;44(3):205-8. [pmid: 1607060].
827 Cundiff GW, Harris RL, Coates KW, et al. Clinical predictors of urinary incontinence in women. Am J Obstet Gynecol. Aug. 1997;177(2):262-6. discussion 6–7. [pmid: 9290438].
828 Holtedahl K, Verelst M, Schiefloe A, et al. Usefulness of urodynamic examination in female urinary incontinence—lessons from a population-based, randomized, controlled study of conservative treatment. Scand J Urol Nephrol. Jun. 2000;34(3):169-74. [pmid: 10961470].
829 Yalcin I, Versi E, Benson JT, et al. Validation of a clinical algorithm to diagnose stress urinary incontinence for large studies. J Urol. Jun. 2004;171(6 Pt 1):2321-5. [pmid: 15126813].
830 Diokno AC, Wells TJ, Brink CA. Urinary incontinence in elderly women: urodynamic evaluation. J Am Geriatr Soc. Oct. 1987;35(10):940-6. [pmid: 3655177].
831 Diokno AC, Normolle DP, Brown MB, et al. Urodynamic tests for female geriatric urinary incontinence. Urology. Nov. 1990;36(5):431-9. [pmid: 2238302].
832 FitzGerald MP, Brubaker L. Urinary incontinence symptom scores and urodynamic diagnoses. Neurourol Urodyn. 2002;21(1):30-5. [pmid: 11835421].
833 Ishiko O, Hirai K, Sumi T, et al. The urinary incontinence score in the diagnosis of female urinary incontinence. Int J Gynaecol Obstet. Feb. 2000;68(2):131-7. [pmid: 10717817].
834 Korda A, Krieger M, Hunter P, et al. The value of clinical symptoms in the diagnosis of urinary incontinence in the female. Aust N Z J Obstet Gynaecol. May. 1987;27(2):149-51. [pmid: 3675441].
835 Kujansuu E, Kauppila A. Scored urological history and urethrocystometry in the differential diagnosis of female urinary incontinence. Ann Chir Gynaecol. 1982;71(4):197-202. [pmid: 6889831].
836 Lagro-Janssen AL, Debruyne FM, van Weel C. Value of the patient's case history in diagnosing urinary incontinence in general practice. Br J Urol. Jun. 1991;67(6):569-72. [pmid: 2070199].
837 Niecestro RM, Wheeler JS Jr, Nanninga J, et al. Use of stresscath for diagnosing stress incontinence. Urology. Mar. 1992;39(3):266-9. [pmid: 1546422].
838 Ouslander J, Staskin D, Raz S, et al. Clinical versus urodynamic diagnosis in an incontinent geriatric female population. J Urol. Jan. 1987;137(1):68-71. [pmid: 3795368].
839 Ramsay IN, Hilton P, Rice N. The symptomatic characterization of patients with detrusor instability and those with genuine stress incontinence. International Urogynecology Journal. 1993;4:23-6.
840 Sand PK, Hill RC, Ostergard DR. Incontinence history as a predictor of detrusor stability. Obstet Gynecol. Feb. 1988;71(2):257-60. [pmid: 3336562].
841 Sandvik H, Hunskaar S, Vanvik A, et al. Diagnostic classification of female urinary incontinence: an epidemiological survey corrected for validity. J Clin Epidemiol. Mar. 1995;48(3):339-43. [pmid: 7897455].
842 Sunshine T, J, Glowacki GA. Clinical correlation of urodynamic testing in patients with urinary incontinence. Journal of Gynecologic Surgery. 1989;5:93-8.
843 Cantor TJ, Bates CP. A comparative study of symptoms and objective urodynamic findings in 214 incontinent women. Br J Obstet Gynaecol. Oct. 1980;87(10):889-92. [pmid: 7191720].
844 Weidner AC, Myers ER, Visco AG, et al. Which women with stress incontinence require urodynamic evaluation?. Am J Obstet Gynecol. Jan. 2001;184(2):20-7. [pmid: 11174474].
845 Bergman A, Bader K. Reliability of the patient's history in the diagnosis of urinary incontinence. Int J Gynaecol Obstet. Jul. 1990;32(3):255-9. [pmid: 1972118].
846 Le Coutour X, Jung-Faerber S, Klein P, et al. Female urinary incontinence: comparative value of history and urodynamic investigations. Eur J Obstet Gynecol Reprod Biol. Dec. 1990;37(3):279-86. [pmid: 2227071].
847 Petros PP, Ulmsten U. Urge incontinence history is an accurate predictor of urge incontinence. Acta Obstet Gynecol Scand. Oct. 1992;71(7):537-9. [pmid: 1332374].
848 van Waalwijk van Doorn ES, Ambergen AW, Janknegt RA. Detrusor activity index: quantification of detrusor overactivity by ambulatory monitoring. J Urol. Feb. 1997;157(2):596-9. [pmid: 8996366].
849 Ficazzola MA, Nitti VW. The etiology of post-radical prostatectomy incontinence and correlation of symptoms with urodynamic findings. J Urol. Oct. 1998;160(4):1317-20. [pmid: 9751344].
850 Ding YY, Lieu PK, Choo PW. Is the bladder “an unreliable witness” in elderly males with persistent lower urinary tract symptoms?. Geriatr Nephrol Urol. 1997;7(1):17-21. [pmid: 9422435].
851 Porru D, Usai E. Standard and extramural ambulatory urodynamic investigation for the diagnosis of detrusor instability-correlated incontinence and micturition disorders. Neurourol Urodyn. 1994;13(3):237-42. [pmid: 7920680].
852 Digesu GA, Khullar V, Cardozo L, et al. Overactive bladder symptoms: do we need urodynamics?. Neurourol Urodyn. 2003;22(2):105-8. [pmid: 12579626].
853 Clarke B. The role of urodynamic assessment in the diagnosis of lower urinary tract disorders. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):196-9. [pmid: 9449295].
854 Kong TK, Morris JA, Robinson JM, et al. Predicting urodynamic dysfunction from clinical features in incontinent elderly women. Age Ageing. Jul. 1990;19(4):257-63. [pmid: 2220485].
855 Avery KN, Bosch JL, Gotoh M, et al. Questionnaires to assess urinary and anal incontinence: review and recommendations. J Urol. Jan. 2007;177(1):39-49. [pmid: 17161997].
856 Avery K, Donovan J, Peters TJ, et al. ICIQ: a brief and robust measure for evaluating the symptoms and impact of urinary incontinence. Neurourol Urodyn. 2004;23(4):322-30. [pmid: 15227649].
857 Brookes ST, Donovan JL, Wright M, et al. A scored form of the Bristol Female Lower Urinary Tract Symptoms questionnaire: data from a randomized controlled trial of surgery for women with stress incontinence. Am J Obstet Gynecol. Jul. 2004;191(1):73-82. [pmid: 15295345].
858 Kulseng-Hanssen S, Borstad E. The development of a questionnaire to measure the severity of symptoms and the quality of life before and after surgery for stress incontinence. BJOG. Nov. 2003;110(11):983-8. [pmid: 14592582].
859 Donovan JL, Peters TJ, Abrams P, et al. Scoring the short form ICSmaleSF questionnaire. International Continence Society. J Urol. Dec. 2000;164(6):1948-55. [pmid: 11061889].
860 Coyne K, Revicki D, Hunt T, et al. Psychometric validation of an overactive bladder symptom and health-related quality of life questionnaire: the OAB-q. Qual Life Res. Sep. 2002;11(6):563-74. [pmid: 12206577].
861 Shumaker SA, Wyman JF, Uebersax JS, et al. Health-related quality of life measures for women with urinary incontinence: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program in Women (CPW) Research Group. Qual Life Res. Oct. 1994;3(5):291-306. [pmid: 7841963].
862 Uebersax JS, Wyman JF, Shumaker SA, et al. Short forms to assess life quality and symptom distress for urinary incontinence in women: the Incontinence Impact Questionnaire and the Urogenital Distress Inventory. Continence Program for Women Research Group. Neurourol Urodyn. 1995;14(2):131-9. [pmid: 7780440].
863 Sandvik H, Hunskaar S, Seim A, et al. Validation of a severity index in female urinary incontinence and its implementation in an epidemiological survey. J Epidemiol Community Health. Dec. 1993;47(6):497-9. [pmid: 8120507]. [pmcid: 1059866].
864 Jackson S, Donovan J, Brookes S, et al. The Bristol Female Lower Urinary Tract Symptoms questionnaire: development and psychometric testing. Br J Urol. Jun. 1996;77(6):805-12. [pmid: 8705212].
865 Donovan JL, Abrams P, Peters TJ, et al. The ICS-‘BPH’ Study: the psychometric validity and reliability of the ICSmale questionnaire. Br J Urol. Apr. 1996;77(4):554-62. [pmid: 8777617].
866 Hald T, Nordling J, Andersen JT, et al. A patient weighted symptom score system in the evaluation of uncomplicated benign prostatic hyperplasia. Scand J Urol Nephrol Suppl. 1991;138:59-62. [pmid: 1723812].
867 Patrick DL, Martin ML, Bushnell DM, et al. Quality of life of women with urinary incontinence: further development of the incontinence quality of life instrument (I-QOL). Urology. Jan. 1999;53(1):71-6. [pmid: 9886591].
868 Stothers L. Reliability, validity, and gender differences in the quality of life index of the SEAPI-QMM incontinence classification system. Neurourol Urodyn. 2004;23(3):223-8. [pmid: 15098217].
869 Kelleher CJ, Cardozo LD, Khullar V, et al. A new questionnaire to assess the quality of life of urinary incontinent women. Br J Obstet Gynaecol. Dec. 1997;104(12):1374-9. [pmid: 9422015].
870 Mouritsen L, Larsen JP. Symptoms, bother and POPQ in women referred with pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):122-7. [pmid: 12851756].
871 Stach-Lempinen B, Kirkinen P, Laippala P, et al. Do objective urodynamic or clinical findings determine impact of urinary incontinence or its treatment on quality of life?. Urology. Jan. 2004;63(1):67-71. discussion -2. [pmid: 14751350].
872 Stach-Lempinen B, Kujansuu E, Laippala P, et al. Visual analogue scale, urinary incontinence severity score and 15 D—psychometric testing of three different health-related quality-of-life instruments for urinary incontinent women. Scand J Urol Nephrol. Dec. 2001;35(6):476-83. [pmid: 11848427].
873 Amarenco G, Arnould B, Carita P, et al. European psychometric validation of the CONTILIFE: a Quality of Life questionnaire for urinary incontinence. Eur Urol. Apr. 2003;43(4):391-404. [pmid: 12667721].
874 Kirschner-Hermanns R, Scherr PA, Branch LG, et al. Accuracy of survey questions for geriatric urinary incontinence. J Urol. Jun. 1998;159(6):1903-8. [pmid: 9598484].
875 Diokno AC, Dimaculangan RR, Lim EU, et al. Office based criteria for predicting type II stress incontinence without further evaluation studies. J Urol. Apr. 1999;161(4):1263-7. [pmid: 10081882].
876 Moore AA, Siu AL. Screening for common problems in ambulatory elderly: clinical confirmation of a screening instrument. Am J Med. Apr. 1996;100(4):438-43. [pmid: 8610731].
877 Richardson DA. Value of the cough pressure profile in the evaluation of patients with stress incontinence. Am J Obstet Gynecol. Oct. 1986;155(4):808-11. [pmid: 3766634].
878 Schick E, Dupont C, Bertrand PE, et al. Predictive value of maximum urethral closure pressure, urethral hypermobility and urethral incompetence in the diagnosis of clinically significant female genuine stress incontinence. J Urol. May. 2004;171(5):1871-5. [pmid: 15076296].
879 Romanzi LJ, Polaneczky M, Glazer HI. Simple test of pelvic muscle contraction during pelvic examination: correlation to surface electromyography. Neurourol Urodyn. 1999;18(6):603-12. [pmid: 10529708].
880 Fischer-Rasmussen W, Hansen RI, Stage P. Predictive values of diagnostic tests in the evaluation of female urinary stress incontinence. Acta Obstet Gynecol Scand. 1986;65(4):291-4. [pmid: 3739640].
881 Resnick NM, Brandeis GH, Baumann MM, et al. Evaluating a national assessment strategy for urinary incontinence in nursing home residents: reliability of the minimum data set and validity of the resident assessment protocol. Neurourol Urodyn. 1996;15(6):583-98. [pmid: 8916112].
882 Summitt RL Jr, Stovall TG, Bent AE, et al. Urinary incontinence: correlation of history and brief office evaluation with multichannel urodynamic testing. Am J Obstet Gynecol. Jun. 1992;166(6 Pt 1):1835-40. discussion 40–4. [pmid: 1615993].
883 Creighton SM, Plevnik S, Stanton SL. Distal urethral electrical conductance (DUEC)—a preliminary assessment of its role as a quick screening test for incontinent women. Br J Obstet Gynaecol. Jan. 1991;98(1):69-72. [pmid: 1998636].
884 Davis G, McClure G, Sherman R, et al. Ambulatory urodynamics of female soldiers. Mil Med. Dec. 1998;163(12):808-12. [pmid: 9866358].
885 Rosario DJ, MacDiarmid SA, Radley SC, et al. A comparison of ambulatory and conventional urodynamic studies in men with borderline outlet obstruction. BJU Int. Mar. 1999;83(4):400-9. [pmid: 10210561].
886 McInerney PD, Vanner TF, Harris SA, et al. Ambulatory urodynamics. Br J Urol. Mar. 1991;67(3):272-4. [pmid: 2021814].
887 Bhatia NN, Bradley WE, Haldeman S, et al. Continuous ambulatory urodynamic monitoring. Br J Urol. Aug. 1982;54(4):357-9. [pmid: 7116100].
888 Swift SE, Ostergard DR. Evaluation of current urodynamic testing methods in the diagnosis of genuine stress incontinence. Obstet Gynecol. Jul. 1995;86(1):85-91. [pmid: 7784028].
889 Versi E. Discriminant analysis of urethral pressure profilometry data for the diagnosis of genuine stress incontinence. Br J Obstet Gynaecol. Mar. 1990;97(3):251-9. [pmid: 2334653].
890 Pajoncini C, Costantini E, Rociola W, et al. The maximum urethral closure pressure and the Valsalva leak point pressure in the diagnosis of intrinsic sphincter deficiency: preliminary results. Acta Urologica Italica. 1999;13:231-5.
891 Versi E, Cardozo L, Cooper DJ. Urethral pressures: analysis of transmission pressure ratios. Br J Urol. Sep. 1991;68(3):266-70. [pmid: 1913067].
892 Cucchi A. Acceleration of flow rate as a screening test for detrusor instability in women with stress incontinence. Br J Urol. Jan. 1990;65(1):17-9. [pmid: 2310926].
893 Swift SE. The reliability of performing a screening cystometrogram using a fetal monitoring device for the detection of detrusor instability. Obstet Gynecol. May. 1997;89(5 Pt 1):708-12. [pmid: 9166306].
894 Bergman A, Nguyen H, Koonings PP, et al. Use of fetal cardiotocographic monitor in the evaluation of urinary incontinence. Isr J Med Sci. Jun. 1988;24(6):291-4. [pmid: 3403225].
895 Petersen T, Chandiramani V, Fowler CJ. The ice-water test in detrusor hyper-reflexia and bladder instability. Br J Urol. Feb. 1997;79(2):163-7. [pmid: 9052463].
896 Sutherst JR, Brown M. Detection of urethral incompetence. Erect studies using the fluid-bridge test. Br J Urol. Aug. 1981;53(4):360-3. [pmid: 7196273].
897 Hanzal E, Berger E, Koelbl H. Reliability of the urethral closure pressure profile during stress in the diagnosis of genuine stress incontinence. Br J Urol. Oct. 1991;68(4):369-71. [pmid: 1933156].
898 Frigerio L, Ferrari A, Candiani GB. The significance of the stop test in female urinary incontinence. Diagn Gynecol Obstet. Winter. 1981;3(4):301-4. [pmid: 7338158].
899 Pelsang RE, Bonney WW. Voiding cystourethrography in female stress incontinence. AJR Am J Roentgenol. Mar. 1996;166(3):561-5. [pmid: 8623628].
900 Scotti RJ, Ostergard DR, Guillaume AA, et al. Predictive value of urethroscopy as compared to urodynamics in the diagnosis of genuine stress incontinence. J Reprod Med. Aug. 1990;35(8):772-6. [pmid: 2213738].
901 Grischke EM, Anton H, Stolz W, et al. Urodynamic assessment and lateral urethrocystography. A comparison of two diagnostic procedures for female urinary incontinence. Acta Obstet Gynecol Scand. 1991;70(3):225-9. [pmid: 1927300].
902 Bergman A, McKenzie C, Ballard CA, et al. Role of cystourethrography in the preoperative evaluation of stress urinary incontinence in women. J Reprod Med. Apr. 1988;33(4):372-6. [pmid: 3367339].
903 Rose DH, Eaton AC. Observations in micturating cystourethrography. J R Soc Med. Feb. 1983;76(2):121-5. [pmid: 6827511]. [pmcid: 1438678].
904 Digesu GA, Khullar V, Cardozo L, et al. The open bladder neck: a significant finding?. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):336-9. [pmid: 15580420].
905 Hsu TH, Rackley RR, Appell RA. The supine stress test: a simple method to detect intrinsic urethral sphincter dysfunction. J Urol. Aug. 1999;162(2):460-3. [pmid: 10411057].
906 Kadar N. The value of bladder filling in the clinical detection of urine loss and selection of patients for urodynamic testing. Br J Obstet Gynaecol. Jul. 1988;95(7):698-704. [pmid: 3415935].
907 Scotti RJ, Myers DL. A comparison of the cough stress test and single-channel cystometry with multichannel urodynamic evaluation in genuine stress incontinence. Obstet Gynecol. Mar. 1993;81(3):430-3. [pmid: 8437800].
908 Resnick NM, Brandeis GH, Baumann MM, et al. Misdiagnosis of urinary incontinence in nursing home women: prevalence and a proposed solution. Neurourol Urodyn. 1996;15(6):599-613. discussion -8. [pmid: 8916113].
909 Lobel RW, Sand PK. The empty supine stress test as a predictor of intrinsic urethral sphincter dysfunction. Obstet Gynecol. Jul. 1996;88(1):128-32. [pmid: 8684745].
910 Ouslander J, Leach G, Abelson S, et al. Simple versus multichannel cystometry in the evaluation of bladder function in an incontinent geriatric population. J Urol. Dec. 1988;140(6):1482-6. [pmid: 3193520].
911 Bergman A, McCarthy TA, Ballard CA, et al. Role of the Q-tip test in evaluating stress urinary incontinence. J Reprod Med. Apr. 1987;32(4):273-5. [pmid: 3585870].
912 Montz FJ, Stanton SL. Q-Tip test in female urinary incontinence. Obstet Gynecol. Feb. 1986;67(2):258-60. [pmid: 3945436].
913 Thomakos N, Young RL, Daskalakis G. The Q-tip test correlation with urethroscopic findings in urinary stress incontinence. Int J Gynaecol Obstet. Dec. 2005;91(3):264-5. [pmid: 16157336].
914 Noblett K, Lane FL, Driskill CS. Does pelvic organ prolapse quantification exam predict urethral mobility in stages 0 and I prolapse?. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):268-71. [pmid: 15856131].
915 Versi E, Orrego G, Hardy E, et al. Evaluation of the home pad test in the investigation of female urinary incontinence. Br J Obstet Gynaecol. Feb. 1996;103(2):162-7. [pmid: 8616134].
916 Seim A, Talseth T, Haukeland H, et al. Validation of a simple patient questionnaire to assist self-detection of overactive bladder. A study in general practice. Scand J Prim Health Care. Dec. 2004;22(4):217-21. [pmid: 15765636].
917 Rockwood TH, Church JM, Fleshman JW, et al. Fecal Incontinence Quality of Life Scale: quality of life instrument for patients with fecal incontinence. Dis Colon Rectum. Jan. 2000;43(1):9-16. discussion -7. [pmid: 10813117].
918 Bug GJ, Kiff ES, Hosker G. A new condition-specific health-related quality of life questionnaire for the assessment of women with anal incontinence. Bjog. Oct. 2001;108(10):1057-67. [pmid: 11702838].
919 Hiller L, Radley S, Mann CH, et al. Development and validation of a questionnaire for the assessment of bowel and lower urinary tract symptoms in women. Bjog. Apr. 2002;109(4):413-23. [pmid: 12013162].