# Appendix D. Technical Expert Panel Members and Affiliation

TEP Member | Affiliation
Linda Brubaker, M.D. | Clinical and Translational Research
| Loyola University Medical Center
Tomas L. Griebling, M.D. | Department of Urology
| The University of Kansas
Robert Madoff, M.D. | Colon and Rectal Surgery
| University of Minnesota Medical School
Richard Nelson, M.D. | Department of General Surgery
| Northern General Hospital, Sheffield, UK
Joseph Ouslander, M.D. | Division of Geriatric Medicine and Gerontology
| Wesley Woods Center of Emory University
Neil Resnick, M.D. | Department of Medicine
| University of Pittsburgh Medical Center
Carolyn Sampselle, Ph.D, R.N.C. | School of Nursing
| University of Michigan
David Thom, M.D., Ph.D. | Family and Community Medicine
| San Francisco General Hospital
Joanne Townsend, R.N., B.A. (Hons) | Urogynaecology Nurse Specialist
Post Grad Cert HSR | University Hospitals of Leicester, Leicester, UK