# Appendix C. List of Excluded Studies

## References

1 Urinary incontinence among hospitalized persons aged 65 years and older—United States, 1984-1987. MMWR Morb Mortal Wkly Rep 1991 Jul 5; 40(26):433–6. Not eligible target population
2 Rectal prolapse. Lancet 1991 Sep 7; 338(8767):605–6. Review
3 Urinary incontinence in adults. Agency for Health Care Policy and Research. Clin Pract Guidel Quick Ref Guide Clin 1992; (2):QR1–27. Guideline
4 High quality long-term care for elderly people. A summary of a report of the Royal College of Physicians and the British Geriatrics Society. J R Coll Physicians Lond 1992 Apr; 26(2):130–3. Review
5 Effects of terodiline on urinary incontinence among older non-institutionalized women. Terodiline in the Elderly American Multicenter Study Group. J Am Geriatr Soc 1993 Sep; 41(9):915–22. Not eligible exposure
6 Professional development. Promoting continence: knowledge for practice (continuing education credit). Nurs Times 1994 Nov 2–8; 90(44):suppl 1–4. Review
7 Goals in continence training. Prof Nurse 1994 Sep; 9(12):783. Review
8 Incontinence. Causes, management and provision of services. A Working Party of the Royal College of Physicians. J R Coll Physicians Lond 1995 Jul–Aug; 29(4):272–4. Review
9 The chief scientist reports .... ‘Incontinence research—the way ahead’ Health Bull (Edinb) 1995 May; 53(3):174–9. Congresses publication
10 Managing acute and chronic urinary incontinence. AHCPR Urinary Incontinence in Adults Guideline Update Panel. Am Fam Physician 1996 Oct; 54(5):1661–72. Review
11 Managing acute and chronic urinary incontinence. U.S. Department of Health and human services. J Am Acad Nurse Pract 1996 Aug; 8(8):390–403. Guideline
12 RU3: making a difference for women. AWHONN's continence research reveals preliminary findings. AWHONN Lifelines 1998 Aug; 2(4):55–6. News
13 Clinical practice guidelines: Neurogenic bowel management in adults with spinal cord injury. Spinal Cord Medicine Consortium. J Spinal Cord Med 1998 Jul; 21(3):248–93. Guideline
14 Continence care. Elder Care 1998 Feb–Mar; 10(1):35. Comment
15 Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 11-1999. A 60-year-old woman with epidural and paraspinal masses. N Engl J Med 1999 Apr 15; 340(15):1188–96. Case-reports
16 Goserelin and locally advanced prostate cancer: new indication. Pros and cons. Prescrire Int 2000 Jun; 9(47):75–6. Comment
17 Biofeedback in the treatment of urinary incontinence in adults. Tecnologica MAP Suppl 2000 Apr:3–5. Not eligible target population
18 Solutions for declining bladder control. Johns Hopkins Med Lett Health After 50 2001 Jul; 13(5):6–7. Comment
19 Patient information. Understanding urinary incontinence. Adv Nurse Pract 2001 Mar; 9(3):64. Patient Education Handout
20 Market research on urinary incontinence offers insightful findings. Urol Nurs 2001 Dec; 21(6):413. News
21 I've been having problems controlling my bowels and have had some “accidents” lately. Is this common? Can it be helped? Mayo Clin Health Lett 2001 Mar; 19(3):8. Comment
22 Page for patients. Menopause. Prev Med 2001 Mar; 32(3):207–8. Patient Education Handout
23 Simpler solutions for incontinence. Health News 2002 Sep; 8(9):9. News
24 Behavior therapy and urge incontinence. Mayo Clin Health Lett 2003 May; 21(5):4. News
25 New treatment for fecal incontinence. Health News 2004 Jul; 10(7):11. News
26 Summaries for patients. Factors associated with acute kidney infections in healthy women. Ann Intern Med 2005 Jan 4; 142(1):I34. Patient Education Handout
27 Many effective treatments for urinary incontinence. There's no need to suffer in silence; there are many treatments and therapies for this disorder. Health News 2006 Aug; 12(8):7–8. News
28 Summaries for patients. A simple test to diagnose urinary incontinence in women. Ann Intern Med 2006 May 16; 144(10):I30. Patient Education Handout
29 Promoting urinary continence in older people. Nurs Older People 2006 Apr; 18(3):35–6. Comment
30 Elderly care. Controlling interest. Health Serv J 2006 Nov 23; 116(6033):26–7. Comment
31 When nature calls too often. Johns Hopkins Med Lett Health After 50 2006 Nov; 18(9):4–5. Comment
32 Aanestad O, Flink R. Interference pattern in perineal muscles. A quantitative electromyographic study in patients with faecal incontinence. Eur J Surg. Feb. 1994;160(2):111-8. Case-series. [pmid: 8193207].
33 Aanestad O, Flink R. Urinary stress incontinence. A urodynamic and quantitative electromyographic study of the perineal muscles. Acta Obstet Gynecol Scand. Mar. 1999;78(3):245-53. Not eligible outcomes. [pmid: 10078588].
34 Aanestad O, Flink R, Haggman M, et al. Interference pattern in the urethral sphincter: a quantitative electromyographic study in patients before and after radical retropubic prostatectomy. Scand J Urol Nephrol. Dec. 1998;32(6):378-82. Not eligible outcomes. [pmid: 9924999].
35 Aaron R, Muliyil J, Abraham S. Medico-social dimensions of menopause: a cross-sectional study from rural south India. Natl Med J India. Jan–Feb. 2002;15(1):14-7. Not eligible level of evidence. [pmid: 11855585].
36 Abayomi J, Kirwan J, Hackett A, et al. A study to investigate women's experiences of radiation enteritis following radiotherapy for cervical cancer. J Hum Nutr Diet. Oct. 2005;18(5):353-63. Case-series. [pmid: 16150131].
37 Abbas F, Siddiqui K, Biyabani SR, et al. Early surgical results with intent to treat by radical retropubic prostatectomy for clinically localized prostate cancer. J Pak Med Assoc. May. 2002;52(5):200-5. Case-series. [pmid: 12174491].
38 Abbas SM, Bissett IP, Neill ME, et al. Long-term results of the anterior Delorme's operation in the management of symptomatic rectocele. Dis Colon Rectum. Feb. 2005;48(2):317-22. Case-series. [pmid: 15812584].
39 Abbas SM, Bissett IP, Neill ME, et al. Long-term outcome of postanal repair in the treatment of faecal incontinence. ANZ J Surg. Sep. 2005;75(9):783-6. Case-series. [pmid: 16173992].
40 Abbasakoor F, Nelson M, Beynon J, et al. Anal endosonography in patients with anorectal symptoms after haemorrhoidectomy. Br J Surg. Nov. 1998;85(11):1522-4. Not eligible target population. [pmid: 9823915].
41 Abdelghany S, Hughes J, Lammers J, et al. Biofeedback and electrical stimulation therapy for treating urinary incontinence and voiding dysfunction: one center's experience. Urol Nurs 2001 Dec; 21(6):401–5, 10. No associative hypothesis tested
42 Abdel-Hady el S, Constantine G. Outcome of the use of tension-free vaginal tape in women with mixed urinary incontinence, previous failed surgery, or low valsalva pressure. J Obstet Gynaecol Res. Feb. 2005;31(1):38-42. Case-series. [pmid: 15669990].
43 Abercrombie JF, Rogers J, Swash M. Faecal incontinence in myotonic dystrophy. J Neurol Neurosurg Psychiatry. Jan. 1998;64(1):128-30. Case-reports. [pmid: 9436743]. [pmcid: 2169926].
44 Abes M, Sarihan H, Madenci E. Evaluation of bone mineral density with dual x-ray absorptiometry for osteoporosis in children with bladder augmentation. J Pediatr Surg. Feb. 2003;38(2):230-2. Not eligible target population. [pmid: 12596110].
45 Abicht-Swensen LM, Debner LK. The Minimum Data Set 2.0: a functional assessment to predict mortality in nursing home residents. Am J Hosp Palliat Care. May–Jun. 1999;16(3):527-32. Not eligible target population. [pmid: 10661060].
46 Aboseif S, Tamaddon K, Chalfin S, et al. Sacral neuromodulation as an effective treatment for refractory pelvic floor dysfunction. Urology. Jul. 2002;60(1):52-6. Not eligible target population.
47 Aboseif SR, Borirakchanyavat S, Lue TF, et al. Continence mechanism of the ileal neobladder in women: a urodynamics study. World J Urol. 1998;16(6):400-4. Case-series. [pmid: 9870288].
48 Aboseif SR, Konety B, Schmidt RA, et al. Preoperative urodynamic evaluation: does it predict the degree of urinary continence after radical retropubic prostatectomy?. Urol Int. 1994;53(2):68-73. Not eligible outcomes. [pmid: 7801419].
49 Aboseif SR, O'Connell HE, Usui A, et al. Collagen injection for intrinsic sphincteric deficiency in men. J Urol. Jan. 1996;155(1):10-3. Case-series. [pmid: 7490800].
50 Abouassaly R, Lane BR, Lakin MM, et al. Ejaculatory urine incontinence after radical prostatectomy. Urology. Dec. 2006;68(6):1248-52. Case-series. [pmid: 17141827].
51 Abouassaly R, Steinberg JR, Lemieux M, et al. Complications of tension-free vaginal tape surgery: a multi-institutional review. BJU Int. Jul. 2004;94(1):110-3. Case-series. [pmid: 15217442].
52 Abou-Zeid AA. Preliminary experience in management of fecal incontinence caused by internal anal sphincter injury. Dis Colon Rectum. Feb. 2000;43(2):198-202. discussion -4. Case-series. [pmid: 10696894].
53 Abramov Y, Gandhi S, Goldberg RP, et al. Site-specific rectocele repair compared with standard posterior colporrhaphy. Obstet Gynecol. Feb. 2005;105(2):314-8. Not eligible outcomes. [pmid: 15684158].
54 Abramov Y, Goldberg RP, McGuire M, et al. Eosinophilic cystitis after bladder instillation with dimethyl sulfoxide. Urology. Jun. 2004;63(6):1182-3. Case-reports.
55 Abrams P, Blaivas JG, Fowler CJ, et al. The role of neuromodulation in the management of urinary urge incontinence. BJU Int. Mar. 2003;91(4):355-9. Secondary data analysis. [pmid: 12603414].
56 Abrams P, Cardozo L, Chapple C, et al. Comparison of the efficacy, safety, and tolerability of propiverine and oxybutynin for the treatment of overactive bladder syndrome. Int J Urol. Jun. 2006;13(6):692-8. Not eligible target population. [pmid: 16834644].
57 Abrams P, Donovan JL, de la Rosette JJ, et al. International Continence Society “Benign Prostatic Hyperplasia” Study: background, aims, and methodology. Neurourol Urodyn. 1997;16(2):79-91. Not eligible outcomes. [pmid: 9042670].
58 Abrams P, Kaplan S, De Koning Gans HJ, et al. Safety and tolerability of tolterodine for the treatment of overactive bladder in men with bladder outlet obstruction. J Urol. Mar. 2006;175(3 Pt 1):999-1004. discussion Not eligible exposure. [pmid: 16469601].
59 Abu J, Wong MY, Foo KT, et al. A case report on vesico-uterine fistula: a very rare complication of the lower caesarean section. Singapore Med J. Nov. 2000;41(11):554-6. Case-reports. [pmid: 11284616].
60 Achtergael W, Michielsen D, Gorus FK, et al. Indoxyl sulphate and the purple urine bag syndrome: a case report. Acta Clin Belg. Jan–Feb. 2006;61(1):38-41. Case Reports. [pmid: 16673616].
61 Adams C, Lorish C, Cushing C, et al. Anatomical urinary stress incontinence in women with rheumatoid arthritis: its frequency and coping strategies. Arthritis Care Res. Jun. 1994;7(2):97-103. Not eligible level of evidence. [pmid: 7858000].
62 Adams D, Samuel D, Goulon-Goeau C, et al. The course and prognostic factors of familial amyloid polyneuropathy after liver transplantation. Brain. Jul. 2000;123(Pt 7):1495-504. Not eligible outcomes. [pmid: 10869060].
63 Adams JB 2nd, Micali S, Moore RG, et al. Complications of extraperitoneal balloon dilation. J Endourol. Aug. 1996;10(4):375-8. Case Reports. [pmid: 8872738].
64 Adang EM, Engel GL, Rutten FF, et al. Cost-effectiveness of dynamic graciloplasty in patients with fecal incontinence. Dis Colon Rectum. Jun. 1998;41(6):725-33. discussion 33–4. Not eligible target population. [pmid: 9645740].
65 Addington-Hall J, Lay M, Altmann D, et al. Symptom control, communication with health professionals, and hospital care of stroke patients in the last year of life as reported by surviving family, friends, and officials. Stroke. Dec. 1995;26(12):2242-8. Not eligible outcomes. [pmid: 7491644].
66 Addison R, Dodd L, Abili J, et al. Stroke, catheters and constipation: action plans. Nurs Times. Jul 26–Aug 1. 2001;97(30):54-5. Case Reports. [pmid: 11957959].
67 Adekanmi OA, Freeman RM, Reed H, et al. Improving the diagnosis of genuine stress incontinence in symptomatic women with negative cough stress test: the Distal Urethral Electrical Conductance test (DUEC) revisited. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):9-12. discussion Not eligible outcomes. [pmid: 12601509].
68 Adkins VK, Mathews RM. Prompted voiding to reduce incontinence in community-dwelling older adults. J Appl Behav Anal. Spring. 1997;30(1):153-6. Case-series. [pmid: 9103990]. [pmcid: 1284028].
69 Adler US, Kirshblum SC. A new assistive device for intermittent self-catheterization in men with tetraplegia. J Spinal Cord Med. Summer. 2003;26(2):155-8. Case-series. [pmid: 12828294].
70 Agachan F, Pfeifer J, Joo JS, et al. Results of perineal procedures for the treatment of rectal prolapse. Am Surg. Jan. 1997;63(1):9-12. Case-series. [pmid: 8985063].
71 Agachan F, Pfeifer J, Wexner SD. Defecography and proctography. Results of 744 patients. Dis Colon Rectum. Aug. 1996;39(8):899-905. Not eligible outcomes. [pmid: 8756846].
72 Agachan F, Reissman P, Pfeifer J, et al. Comparison of three perineal procedures for the treatment of rectal prolapse. South Med J. Sep. 1997;90(9):925-32. Case-series. [pmid: 9305305].
73 Agarwal A, Dhiraaj S, Singhal V, et al. Comparison of efficacy of oxybutynin and tolterodine for prevention of catheter related bladder discomfort: a prospective, randomized, placebo-controlled, double-blind study. Br J Anaesth. Mar. 2006;96(3):377-80. Not eligible outcomes. [pmid: 16415311].
74 Aghaji AE, Odoemene C. Ureteric injuries in Enugu, Nigeria. East Afr Med J. Apr. 1999;76(4):184-8. Case-series. [pmid: 10442098].
75 Agnew G, Byrne P. The evaluation and treatment of female urinary incontinence—a comparison of clinical practice in the Republic of Ireland with the recommendations of the International Continence Society. Ir Med J. Sep. 2004;97(8):238-40. Not eligible outcomes. [pmid: 15532970].
76 Agostini A, De Lapparent T, Bretelle F, et al. Abscess of the thigh and psoas muscle after transobturator suburethral sling procedure. Acta Obstet Gynecol Scand. 2006;85(5):628-9. Case report. [pmid: 16752248].
77 Aharon-Peretz J, Kliot D, Finkelstein R, et al. Cryptococcal meningitis mimicking vascular dementia. Neurology. Jun 8. 2004;62(11):2135. Case Reports. [pmid: 15184639].
78 Ahlering TE, Skarecky D, Lee D, et al. Successful transfer of open surgical skills to a laparoscopic environment using a robotic interface: initial experience with laparoscopic radical prostatectomy. J Urol. Nov. 2003;170(5):1738-41. Case-series. [pmid: 14532766].
79 Ahlering TE, Weinberg AC, Razor B. Modified Indiana pouch. J Urol. Jun. 1991;145(6):1156-8. Case-series. [pmid: 2033683].
80 Ahn SC, Brown AW. Cobalamin deficiency and subacute combined degeneration after nitrous oxide anesthesia: a case report. Arch Phys Med Rehabil. Jan. 2005;86(1):150-3. Case-reports. [pmid: 15641006].
81 Ahn SM, Han SW, Choi SH. The results of antegrade continence enema using a retubularized sigmoidostomy. Pediatr Surg Int. Jul. 2004;20(7):488-91. Not eligible target population. [pmid: 15278377].
82 Aitchison M, Fisher BM, Carter K, et al. Impaired anal sensation and early diabetic faecal incontinence. Diabet Med. Dec. 1991;8(10):960-3. Not eligible exposure. [pmid: 1838049].
83 Aitola P, Hiltunen KM, Matikainen M. Functional results of anterior levatorplasty and external sphincter plication for faecal incontinence. Ann Chir Gynaecol. 2000;89(1):29-32. Case-series. [pmid: 10791642].
84 Aitola PT, Hiltunen KM, Matikainen MJ. Functional results of operative treatment of rectal prolapse over an 11-year period: emphasis on transabdominal approach. Dis Colon Rectum. May. 1999;42(5):655-60. Case-series. [pmid: 10344689].
85 Akpinar H, Cetinel B, Demirkesen O, et al. Long-term results of Burch colposuspension. Int J Urol. Apr. 2000;7(4):119-25. Case-series. [pmid: 10810967].
86 al Baba N, Spencer P, Bower C, et al. Continence management. Perspectives. Fall. 2000;24(3):9-15. Comment. [pmid: 12026291].
87 Al-Abany M, Helgason AR, Adolfsson J, et al. Reliability of assessment of urgency and other symptoms indicating anal sphincter, large bowel or urinary dysfunction. Scand J Urol Nephrol. 2006;40(5):397-408. Not eligible outcomes. [pmid: 17060087].
88 al-Abany M, Helgason AR, Cronqvist AK, et al. Toward a definition of a threshold for harmless doses to the anal-sphincter region and the rectum. Int J Radiat Oncol Biol Phys. Mar 15. 2005;61(4):1035-44. Case-series. [pmid: 15752882].
89 Alappat JP. Scimitar sacrum. Neurol India. Jun. 2004;52(2):288. Case report. [pmid: 15269512].
90 Al-Badr A, Fouda K. Suprapubic-assisted cystoscopic excision of intravesical tension-free vaginal tape. J Minim Invasive Gynecol. Jul–Aug. 2005;12(4):370-1. Case Reports. [pmid: 16036201].
91 Albani JM, Zippe CD. Urethral catheter removal 3 days after radical retropubic prostatectomy is feasible and desirable. Prostate Cancer Prostatic Dis. 2002;5(4):291-5. Not eligible exposure. [pmid: 12627214].
92 Albayrak S, Goktas C, Canguven O. Use of atresic vagina as a urethra to repair iatrogenic incontinence, secondary to a complete longitudinal urethral incision. Int J Urol. Mar. 2005;12(3):325-7. Case Reports. [pmid: 15828967].
93 Albertsen PC. Clinical and physical determinants for toxicity of 125-I seed prostate brachytherapy. J Urol. Nov. 2005;174(5):1969-70. Comment.
94 Albouy B, Grise P, Sambuis C, et al. Pediatric urinary incontinence: evaluation of bladder wall wraparound sling procedure. J Urol. Feb. 2007;177(2):716-9. Case-series. [pmid: 17222665].
95 Albright TS, Garlich CL, Iglesia CB. Complications after laparoscopic burch with hernia mesh and surgical tacks. Obstet Gynecol. Sep. 2006;108(3 Pt 2):718-20. Case Reports. [pmid: 17018476].
96 Alcalay M, Thompson PK, Boone TB. Ball urethroplasty combined with Marshall-Marchetti-Krantz urethropexy versus suburethral sling in patients with intrinsic sphincter deficiency and urethral hypermobility. Am J Obstet Gynecol. Dec. 2000;183(6):1348-53. discussion 53–4. Case-series. [pmid: 11120495].
97 Alcini E, Racioppi M, D'Addessi A, et al. The ileocaeco-urethrostomy with multiple transverse taeniamyotomies for bladder replacement: an alternative to detubularized neobladders. Morphological, functional and metabolic results after 9 years' experience. Br J Urol. Mar. 1997;79(3):333-8. Case-series. [pmid: 9117210].
98 Alessi CA, Schnelle JF, MacRae PG, et al. Does physical activity improve sleep in impaired nursing home residents?. J Am Geriatr Soc. Oct. 1995;43(10):1098-102. Not eligible outcomes. [pmid: 7560698].
99 Alessi CA, Schnelle JF, Traub S, et al. Psychotropic medications in incontinent nursing home residents: association with sleep and bed mobility. J Am Geriatr Soc. Jul. 1995;43(7):788-92. Not eligible outcomes. [pmid: 7602033].
100 Alessi CA, Yoon EJ, Schnelle JF, et al. A randomized trial of a combined physical activity and environmental intervention in nursing home residents: do sleep and agitation improve?. J Am Geriatr Soc. Jul. 1999;47(7):784-91. Not eligible outcomes. [pmid: 10404920].
101 Alexander AA, Liu JB, Merton DA, et al. Fecal incontinence: transvaginal US evaluation of anatomic causes. Radiology. May. 1996;199(2):529-32. Case-series. [pmid: 8668806].
102 Al-Fahad T, Ismael A, Soliman MO, et al. Very early onset of Wernicke's encephalopathy after gastric bypass. Obes Surg. May. 2006;16(5):671-2. Case-reports. [pmid: 16687041].
103 Alford DM. How do you carry out the Healthy People 2000 and the United States Preventive Services Task Force recommendations on immunizations, use of hormone replacement therapy, and prevention of incontinence in your older clients? Identify client information handouts you provide. J Gerontol Nurs. Oct. 1998;24(10):45-7. Guideline.
104 Alhasso A, Bryden AA, Neilson D. Lithium toxicity after urinary diversion with ileal conduit. Bmj. Apr 15. 2000;320(7241):1037. Case-reports. [pmid: 10764364].
105 Aliabadi H, Gonzalez R. Success of the artificial urinary sphincter after failed surgery for incontinence. J Urol. May. 1990;143(5):987-90. Not eligible target population. [pmid: 2329618].
106 Al-Jadid MS, Al-Asmari AK, Al-Moutaery KR. Quality of life in males with spinal cord injury in Saudi Arabia. Saudi Med J. Dec. 2004;25(12):1979-85. Cse-series. [pmid: 15711680].
107 Allahdin S, McKinley C, Mahmood TA, et al. Tension-free vaginal tape: 162 cases in a district general hospital. J Obstet Gynaecol. Aug. 2004;24(5):539-41. Case-series. [pmid: 15369936].
108 Allahdin S, McKinley CA, Mahmood TA. Tension free vaginal tape: a procedure for all ages. Acta Obstet Gynecol Scand. Oct. 2004;83(10):937-40. Case-series. [pmid: 15453889].
109 Allahdin S, McKinley CA, Mahmood TA, et al. Vaginal wall erosion of the tension-free vaginal tape procedure: an unusual complication. J Obstet Gynaecol. Jul. 2003;23(4):443. Case Reports. [pmid: 12881097].
110 Allareddy V, Kennedy J, West MM, et al. Quality of life in long-term survivors of bladder cancer. Cancer. Jun 1. 2006;106(11):2355-62. Not eligible outcomes. [pmid: 16649218].
111 Allen D. Desperate for improvement. Nurs Older People. Jan. 2006;17(10):7. News. [pmid: 16445216].
112 Allen-Mersh TG, Turner MJ, Mann CV. Effect of abdominal Ivalon rectopexy on bowel habit and rectal wall. Dis Colon Rectum. Jul. 1990;33(7):550-3. Case-series. [pmid: 2361421].
113 Almeida FG, Bruschini H, Srougi M. Urodynamic and clinical evaluation of 91 female patients with urinary incontinence treated with perineal magnetic stimulation: 1-year followup. J Urol. Apr. 2004;171(4):1571-4. discussion 4–5. Not eligible target population. [pmid: 15017223].
114 Almeida SH, Gregorio E, El Sayed S, et al. Variables predictive of voiding disfunction following aponeurotic sling surgery: multivariate analysis. Int Braz J Urol. Jul–Aug. 2004;30(4):302-6. Case-series. [pmid: 15679962].
115 Al-Mulhim AA, Al-Gazzar SA, Bahnassy AA. Conservative treatment of idiopathic detrusor instability in elderly women. Saudi Med J. May. 2002;23(5):543-5. Not eligible target population. [pmid: 12070577].
116 Al-Rifaei MA, Al-Rifaei AM, Al-Angabawy A. Management of urinary incontinence after bulboprostatic anastomotic urethroplasty for posterior urethral obstruction secondary to pelvic fracture. Scand J Urol Nephrol. 2004;38(1):42-6. Not eligible outcomes. [pmid: 15204426].
117 Al-Samarrai NR, Uman GC, Al-Samarrai T, et al. Introducing a new incontinence management system for nursing home residents. J Am Med Dir Assoc. May. 2007;8(4):253-61. Not eligible outcomes. [pmid: 17498610]. [pmcid: 2492984].
118 Al-Shammari SA, Al-Subaie A. Prevalence and correlates of depression among Saudi elderly. Int J Geriatr Psychiatry. Sep. 1999;14(9):739-47. Not eligible level of evidence. [pmid: 10479745].
119 Alstrup NI, Rasmussen OO, Christiansen J. Effect of rectal dilation in fecal incontinence with low rectal compliance. Report of a case. Dis Colon Rectum. Sep. 1995;38(9):988-9. Case-reports. [pmid: 7656750].
120 Altan-Yaycioglu R, Yaycioglu O, Aydin Akova Y, et al. Ocular side-effects of tolterodine and oxybutynin, a single-blind prospective randomized trial. Br J Clin Pharmacol. May. 2005;59(5):588-92. Not eligible outcomes. [pmid: 15842558]. [pmcid: 1884849].
121 Altman D, Lopez A, Falconer C, et al. The impact of hysterectomy on lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):418-23. Case-series. [pmid: 14677004].
122 Altman D, Zetterstrom J, Lopez A, et al. Effect of hysterectomy on bowel function. Dis Colon Rectum. Apr. 2004;47(4):502-8. discussion 8–9. Case-series. [pmid: 14994113].
123 Altomare DF, Dodi G, La Torre F, et al. Multicentre retrospective analysis of the outcome of artificial anal sphincter implantation for severe faecal incontinence. Br J Surg. Nov. 2001;88(11):1481-6. Case-series. [pmid: 11683745].
124 Altomare DF, Rinaldi M, Pannarale O, et al. Vaginal repair of rectocele after dynamic graciloplasty for fecal incontinence due to imperforate anus. Int J Colorectal Dis. 1996;11(5):243-5. Case-reports. [pmid: 8951515].
125 Altomare DF, Rinaldi M, Pannarale OC, et al. Electrostimulated gracilis neosphincter for faecal incontinence and in total anorectal reconstruction: still an experimental procedure?. Int J Colorectal Dis. 1997;12(5):308-12. Case-series. [pmid: 9401848].
126 Altomare DF, Rinaldi M, Petrolino M, et al. Permanent sacral nerve modulation for fecal incontinence and associated urinary disturbances. Int J Colorectal Dis. May. 2004;19(3):203-9. Case-series. [pmid: 13680281].
127 Altomare DF, Rinaldi M, Petrolino M, et al. Reliability of electrophysiologic anal tests in predicting the outcome of sacral nerve modulation for fecal incontinence. Dis Colon Rectum. Jun. 2004;47(6):853-7. Not eligible outcomes. [pmid: 15085439].
128 Altomare DF, Rinaldi M, Sallustio PL, et al. Long-term effects of stapled haemorrhoidectomy on internal anal function and sensitivity. Br J Surg. Nov. 2001;88(11):1487-91. Case-series. [pmid: 11683746].
129 Altomare DF, Rinaldi M, Veglia A, et al. Contribution of posture to the maintenance of anal continence. Int J Colorectal Dis. Feb. 2001;16(1):51-4. Not eligible outcomes. [pmid: 11317698].
130 Alvi T, Reza H. Neuroleptic induced incontinence—case report. J Pak Med Assoc. Jul. 1997;47(7):195-6. Case-reports. [pmid: 9301164].
131 Amarenco G, Bayle B, Ismael SS, et al. Bulbocavernosus muscle responses after suprapubic stimulation: analysis and measurement of suprapubic bulbocavernosus reflex latency. Neurourol Urodyn. 2002;21(3):210-3. Case-series. [pmid: 11948714].
132 Amarenco G, Ismael SS, Even-Schneider A, et al. Urodynamic effect of acute transcutaneous posterior tibial nerve stimulation in overactive bladder. J Urol. Jun. 2003;169(6):2210-5. Not eligible target population. [pmid: 12771752].
133 Amaro JL, Oliveira Gameiro MO, Padovani CR. Treatment of urinary stress incontinence by intravaginal electrical stimulation and pelvic floor physiotherapy. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):204-8. discussion 8. Not eligible target population. [pmid: 12955344].
134 Amaye-Obu FA, Drutz HP. Surgical management of recurrent stress urinary incontinence: A 12-year experience. Am J Obstet Gynecol. Dec. 1999;181(6):1296-307. discussion 307–9. Case-series. [pmid: 10601904].
135 Ambroze WL Jr, Dozois RR, Pemberton JH, et al. Familial adenomatous polyposis: results following ileal pouch-anal anastomosis and ileorectostomy. Dis Colon Rectum. Jan. 1992;35(1):12-5. Case-series. [pmid: 1310269].
136 Ambroze WL, Pemberton JH, Bell AM, et al. The effect of stool consistency on rectal and neorectal emptying. Dis Colon Rectum. Jan. 1991;34(1):1-7. Not eligible exposure. [pmid: 1991415].
137 Ameda K, Kakizaki H, Machino R, et al. Laparoscopic antegrade continence enema procedure for fecal incontinence in a patient with spina bifida. Int J Urol. Jul. 2003;10(7):401-3. Case-reports. [pmid: 12823697].
138 Ameda K, Koyanagi T, Nantani M, et al. The relevance of preoperative cystometrography in patients with benign prostatic hyperplasia: correlating the findings with clinical features and outcome after prostatectomy. J Urol. Aug. 1994;152(2 Pt 1):443-7. Not eligible exposure. [pmid: 7516977].
139 Ames D, Hastie IR. Urinary incontinence. Postgrad Med J. Apr. 1995;71(834):195-7. No associative hypothesis tested. [pmid: 7784273]. [pmcid: 2398052].
140 Amin AI, Hallbook O, Lee AJ, et al. A 5-cm colonic J pouch colo-anal reconstruction following anterior resection for low rectal cancer results in acceptable evacuation and continence in the long term. Colorectal Dis. Jan. 2003;5(1):33-7. Case-series. [pmid: 12780924].
141 Amna MB, Randrianantenaina A, Michel F. Colic perforation as a complication of tension-free vaginal tape procedure. J Urol. Dec. 2003;170(6 Pt 1):2387. Case Reports. [pmid: 14634426].
142 Amoroso L, Pelliccioni G, Ghiselli R, et al. Sacral-neuromodulation CT-guided. Radiol Med (Torino). Apr. 2005;109(4):421-9. Case-series. [pmid: 15883527].
143 Amundsen CL, Flynn BJ, Webster GD. Anatomical correction of vaginal vault prolapse by uterosacral ligament fixation in women who also require a pubovaginal sling. J Urol. May. 2003;169(5):1770-4. Case-series. [pmid: 12686830].
144 Amundsen CL, Guralnick ML, Webster GD. Variations in strategy for the treatment of urethral obstruction after a pubovaginal sling procedure. J Urol. Aug. 2000;164(2):434-7. Case-series. [pmid: 10893603].
145 Amundsen CL, Romero AA, Jamison MG, et al. Sacral neuromodulation for intractable urge incontinence: are there factors associated with cure?. Urology. Oct. 2005;66(4):746-50. Not eligible target population. [pmid: 16230129].
146 Anand KB, Wolf-Klein GP, Silverstone FA, et al. Demographic changes and their financial implications. Clin Geriatr Med. Feb. 1990;6(1):1-12. Review paper; not original data. [pmid: 2302647].
147 Anastasiadis AG, Ebert T, Gerharz CD, et al. Epididymal metastasis of a prostatic carcinoma. Urol Int. 1998;60(2):124-5. Case Reports. [pmid: 9563154].
148 Anastasiadis AG, Salomon L, Katz R, et al. Radical retropubic versus laparoscopic prostatectomy: a prospective comparison of functional outcome. Urology. Aug. 2003;62(2):292-7. Case-Series. [pmid: 12893338].
149 Andersen JT, Sander P. Minimal care—a new concept for the management of urinary incontinence in an open access, interdisciplinary incontinence clinic. The way ahead?. Scand J Urol Nephrol Suppl. 1996;179:55-60. Not eligible exposure. [pmid: 8908665].
150 Anderson CS, Jamrozik KD, Broadhurst RJ, et al. Predicting survival for 1 year among different subtypes of stroke. Results from the Perth Community Stroke Study. Stroke. Oct. 1994;25(10):1935-44. Not eligible outcomes. [pmid: 8091436].
151 Anderson M. Continence. Painting a new picture. Nurs Times. Aug 15–21. 1990;86(33):74. Case Reports. [pmid: 2385546].
152 Anderson P. Continence care: improving services for older people. Community Nurse. Apr. 1997;3(3):26-8. Comment. [pmid: 9451130].
153 Anderson RU, Mobley D, Blank B, et al. Once daily controlled versus immediate release oxybutynin chloride for urge urinary incontinence. OROS Oxybutynin Study Group. J Urol. Jun. 1999;161(6):1809-12. Not eligible exposure. [pmid: 10332441].
154 Andrades M, Paul R, Ambreen A, et al. Distribution of lower urinary tract symptoms (LUTS) in adult women. J Coll Physicians Surg Pak. Mar. 2004;14(3):132-5. Not eligible outcomes. [pmid: 15228842].
155 Andrews BJ, Reynard JM. Transcutaneous posterior tibial nerve stimulation for treatment of detrusor hyperreflexia in spinal cord injury. J Urol. Sep. 2003;170(3):926. Case-reports. [pmid: 12913738].
156 Andrews HO, Shah PJ. Surgical management of urethral damage in neurologically impaired female patients with chronic indwelling catheters. Br J Urol. Dec. 1998;82(6):820-4. Csae-series. [pmid: 9883218].
157 Andreyev HJ, Vlavianos P, Blake P, et al. Gastrointestinal symptoms after pelvic radiotherapy: role for the gastroenterologist?. Int J Radiat Oncol Biol Phys. Aug 1. 2005;62(5):1464-71. Not eligible level of evidence. [pmid: 15927411].
158 Andriesse GI, Gooszen HG, Schipper ME, et al. Functional results and visceral perception after ileo neo-rectal anastomosis in patients: a pilot study. Gut. May. 2001;48(5):683-9. Case-series. [pmid: 11302969]. [pmcid: 1728300].
159 Ang LP, Tay KP, Lim PH, et al. Endoscopic injection of collagen for the treatment of female urinary stress incontinence. Int J Urol. May. 1997;4(3):254-8. Not eligible target population. [pmid: 9255662].
160 Anger JT, Litwin MS, Wang Q, et al. Complications of sling surgery among female Medicare beneficiaries. Obstet Gynecol. Mar. 2007;109(3):707-14. Not eligible outcomes. [pmid: 17329524].
161 Anger JT, Rodriguez LV, Wang Q, et al. Racial disparities in the surgical management of stress incontinence among female Medicare beneficiaries. J Urol. May. 2007;177(5):1846-50. Not eligible outcomes. [pmid: 17437833].
162 Anger JT, Rodriguez LV, Wang Q, et al. The role of provider volume on outcomes after sling surgery for stress urinary incontinence. J Urol. Apr. 2007;177(4):1457-62. discussion 62. Not eligible exposure. [pmid: 17382752].
163 Anger JT, Saigal CS, Madison R, et al. Increasing costs of urinary incontinence among female Medicare beneficiaries. J Urol. Jul. 2006;176(1):247-51. discussion 51. Not eligible outcomes. [pmid: 16753411].
164 Anghelacopoulos SE, Tagarakis GI, Pilpilidis I, et al. Albumin-glutaraldehyde bioadhesive (“Bioglue”) for prevention of postoperative complications after stapled hemorrhoidopexy: A randomized controlled trial. Wien Klin Wochenschr. Aug. 2006;118(1516):469-72. Not eligible exposure. [pmid: 16957977].
165 Angioli R, Gomez-Marin O, Cantuaria G, et al. Severe perineal lacerations during vaginal delivery: the University of Miami experience. Am J Obstet Gynecol. May. 2000;182(5):1083-5. Not eligible outcomes. [pmid: 10819834].
166 Aniuliene R, Bariliene S. New surgical technique for the treatment of urinary incontinence in Clinic of Obstetrics and Gynecology of Kaunas University of Medicine. Medicina (Kaunas). 2006;42(9):725-31. Case-series. [pmid: 17028470].
167 Ankardal M, Heiwall B, Lausten-Thomsen N, et al. Short- and long-term results of the tension-free vaginal tape procedure in the treatment of female urinary incontinence. Acta Obstet Gynecol Scand. 2006;85(8):986-92. Case-series. [pmid: 16862480].
168 Ansquer Y, Marcollet A, Yazbeck C, et al. The suburethral sling for female stress urinary incontinence: a retropubic or obturator approach?. J Am Assoc Gynecol Laparosc. Aug. 2004;11(3):353-8. Not eligible target population. [pmid: 15559348].
169 Antonakos CL, Miller JM, Sampselle CM. Indices for studying urinary incontinence and levator ani function in primiparous women. J Clin Nurs. Jul. 2003;12(4):554-61. Not eligible outcomes. [pmid: 12790869].
170 Antovska SV, Dimitrov DG. Vaginosacral colpopexy (VSC)—a new modification of the Mc Call operation using vaginosacral ligaments as autologous sliding grafts in posthysterectomy vault prolapse. Bratisl Lek Listy. 2006;107(3):62-72. [pmid: 16796126].
171 Apostolidis A, Popat R, Yiangou Y, et al. Decreased sensory receptors P2X3 and TRPV1 in suburothelial nerve fibers following intradetrusor injections of botulinum toxin for human detrusor overactivity. J Urol. Sep. 2005;174(3):977-82. discussion 82–3. Not eligible outcomes. [pmid: 16094018].
172 Appell RA. Clinical efficacy and safety of tolterodine in the treatment of overactive bladder: a pooled analysis. Urology. Dec. 1997;50(6A Suppl):90-6. discussion 7–9. Review and meta-analysis. [pmid: 9426760].
173 Appell RA, Baum N. Evaluation of urinary incontinence in the elderly. J La State Med Soc. Nov. 1992;144(11):517-22. Comment. [pmid: 1431484].
174 Appell RA, Sand P, Dmochowski R, et al. Prospective randomized controlled trial of extended-release oxybutynin chloride and tolterodine tartrate in the treatment of overactive bladder: results of the OBJECT Study. Mayo Clin Proc. Apr. 2001;76(4):358-63. Not eligible exposure. [pmid: 11322350].
175 Appell RA, Vasavada SP, Rackley RR, et al. Percutaneous antegrade collagen injection therapy for urinary incontinence following radical prostatectomy. Urology. Nov. 1996;48(5):769-72. Not eligible target population. [pmid: 8911523].
176 Aprikian A, Berardinucci G, Pike J, et al. Experience with the AS-800 artificial urinary sphincter in myelodysplastic children. Can J Surg. Aug. 1992;35(4):396-400. Not eligible target population. [pmid: 1498739].
177 Arai Y, Okubo K, Aoki Y, et al. Patient-reported quality of life after radical prostatectomy for prostate cancer. Int J Urol. Feb. 1999;6(2):78-86. Case-series. [pmid: 10226812].
178 Arai Y, Taki Y, Kawase N, et al. Orthotopic ileal neobladder in male patients: functional outcomes of 66 cases. Int J Urol. Aug. 1999;6(8):388-92. Case-series. [pmid: 10466450].
179 Araki I, Du S, Kamiyama M, et al. Overexpression of epithelial sodium channels in epithelium of human urinary bladder with outlet obstruction. Urology. Dec. 2004;64(6):1255-60. Not eligible outcomes. [pmid: 15596218].
180 Araki Y, Isomoto H, Tsuzi Y, et al. Transsacral rectopexy for complete rectal prolapse. Kurume Med J. 1998;45(3):235-8. Case-reports. [pmid: 9787592].
181 Araki Y, Isomoto H, Tsuzi Y, et al. Transsacral rectopexy for recurrent complete rectal prolapse. Surg Today. 1999;29(9):970-2. Case-reports. [pmid: 10489150].
182 Arena MG, Di Rosa AE, Arcudi L, et al. Voiding disorders in patients with cerebrovascular disease. Funct Neurol. Jan–Feb. 1992;7(1):47-9. Case-series. [pmid: 1582579].
183 Armstrong RB, Luber KM, Peters KM. Comparison of dry mouth in women treated with extended-release formulations of oxybutynin or tolterodine for overactive bladder. Int Urol Nephrol. 2005;37(2):247-52. Not eligible outcomes. [pmid: 16142551].
184 Arnaud A, Sarles JC, Sielezneff I, et al. Sphincter repair without overlapping for fecal incontinence. Dis Colon Rectum. Sep. 1991;34(9):744-7. Case-series. [pmid: 1914736].
185 Aron M, Manal K, Gupta NP. Urinary incontinence: an unusual manifestation of a forgotten stent. Br J Urol. May. 1998;81(5):766-7. Case Reports. [pmid: 9634062].
186 Aronovitch SA. A descriptive study of the career mobility of ET nurses. J Wound Ostomy Continence Nurs. Jul. 1995;22(4):166-72. Not eligible target population. [pmid: 7627290].
187 Aronson MP, Bates SM, Jacoby AF, et al. Periurethral and paravaginal anatomy: an endovaginal magnetic resonance imaging study. Am J Obstet Gynecol. Dec. 1995;173(6):1702-8. discussion 8–10. Not eligible outcomes. [pmid: 8610748].
188 Aronson MP, Lee RA, Berquist TH. Anatomy of anal sphincters and related structures in continent women studied with magnetic resonance imaging. Obstet Gynecol. Nov. 1990;76(5 Pt 1):846-51. Case-series. [pmid: 2216237].
189 Arpa Gutierrez J, Morales C, Lara M, et al. Type I familial amyloid polyneuropathy and pontine haemorrhage. Acta Neuropathol (Berl). 1993;86(5):542-5. Case Reports. [pmid: 8310808].
190 Arrowsmith SD. Genitourinary reconstruction in obstetric fistulas. J Urol. Aug. 1994;152(2 Pt 1):403-6. Case-series. [pmid: 8015081].
191 Arruda RM, Castro RA, Sartori MG, et al. Clinical and urodynamic evaluation of women with detrusor instability before and after functional pelvic floor electrostimulation. Clin Exp Obstet Gynecol. 2003;30(4):220-2. Case-series. [pmid: 14664417].
192 Arumugam PJ, Patel B, Rieck G, et al. Are obstetric risk factors and bowel symptoms associated with defaecographic and manometric abnormalities in women awaiting hysterectomy?. J Obstet Gynaecol. Apr. 2004;24(3):274-8. Case-series. [pmid: 15203625].
193 Arunkalaivanan AS, Barrington JW. Questionnaire-based survey on obstetricians and gynaecologists' attitudes towards the surgical management of urinary incontinence in women during their childbearing years. Eur J Obstet Gynecol Reprod Biol. May 1. 2003;108(1):85-93. Not eligible outcomes. [pmid: 12694977].
194 Arunkalaivanan AS, Smith AR. Bladder calculus after laparoscopic colposuspension. J Obstet Gynaecol. Jan. 2002;22(1):101. Case Reports. [pmid: 12521751].
195 Arya LA, Myers DL, Jackson ND. Dietary caffeine intake and the risk for detrusor instability: a case-control study. Obstet Gynecol. Jul. 2000;96(1):85-9. Not eligible target population. [pmid: 10862848].
196 Ashworth PD, Hagan MT. The meaning of incontinence: a qualitative study of non-geriatric urinary incontinence sufferers. J Adv Nurs. Sep. 1993;18(9):1415-23. Not eligible outcomes. [pmid: 8258600].
197 Aslan E, Beji NK, Coskun A, et al. An assessment of the importance of pad testing in stress urinary incontinence and the effects of incontinence on the life quality of women. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):316-9. discussion 20. Not eligible outomces. [pmid: 14618307].
198 Aslan G, Koseoglu H, Sadik O, et al. Sexual function in women with urinary incontinence. Int J Impot Res. May–Jun. 2005;17(3):248-51. Not eligible outcomes. [pmid: 15592424].
199 Aslan V, Akay OM, Durak B, et al. Langerhans cell histiocytosis with transformation to acute leukemia showing 45,X, t(8; 21), 5q-, -Y karyotype. Leuk Lymphoma. Aug. 2002;43(8):1683-5. Case Reports. [pmid: 12400613].
200 Atahan O, Kayigil O, Metin A. Modified four corner bladder neck suspension in anatomical stress incontinence with moderate cystocele. Int Urol Nephrol. 1998;30(4):439-44. Case-series. [pmid: 9821046].
201 Atala A, Bauer SB, Dyro FM, et al. Bladder functional changes resulting from lipomyelomeningocele repair. J Urol. Aug. 1992;148(2 Pt 2):592-4. Not eligible target population. [pmid: 1640529].
202 Atan A, Konety BR, Erickson JR, et al. Tolterodine for overactive bladder: time to onset of action, preferred dosage, and 9-month follow-up. Tech Urol. Jun. 1999;5(2):67-70. Not eligible target population. [pmid: 10458657].
203 Athanasiou S, Khullar V, Boos K, et al. Imaging the urethral sphincter with three-dimensional ultrasound. Obstet Gynecol. Aug. 1999;94(2):295-301. Not eligible outcomes. [pmid: 10432146].
204 Athanasopoulos A, Barlas P, Perimenis P, et al. Long-term results of transvaginal colposuspension for the treatment of genuine stress incontinence combined with vaginal hysterectomy. Urol Int. 2003;71(1):41-4. Case-series. [pmid: 12845259].
205 Athanasopoulos A, Liatsikos EN, Perimenis P, et al. Delayed suture intravesical migration as a complication of a Stamey endoscopic bladder neck suspension. Int Urol Nephrol. 2002;34(1):5-7. Case-reports. [pmid: 12549629].
206 Athanasopoulos A, Perimenis P, Giannitsas K, et al. The relationship between the perineal length measurements and the urodynamic stress incontinence. Int Urol Nephrol. 2005;37(4):701-5. Not eligible level of evidence. [pmid: 16362583].
207 Athanassopoulos A, Barbalias G. Burch colposuspension versus stamey endoscopic bladder neck suspension: a urodynamic appraisal. Urol Int. 1996;56(1):23-7. Case-Series.
208 Athanassopoulos A, Melekos MD, Speakman M, et al. Stamey endoscopic vesical neck suspension in female urinary stress incontinence: results and changes in various urodynamic parameters. Int Urol Nephrol. 1994;26(3):293-9. Not eligible target population. [pmid: 7960540].
209 Athanassopoulos A, Perimenis P, Markou S, et al. Prognostic factors for the operative correction of stress urinary incontinence. Int Urol Nephrol. 1995;27(1):43-9. Not eligible outcomes. [pmid: 7615370].
210 Auguste T, Dubreuil A, Bost R, et al. Technical and functional results after laparoscopic rectopexy to the promontory for complete rectal prolapse. Prospective study in 54 consecutive patients. Gastroenterol Clin Biol. May. 2006;30(5):659-63. Case-series. [pmid: 16801887].
211 Aukee P, Usenius JP, Kirkinen P. An evaluation of pelvic floor anatomy and function by MRI. Eur J Obstet Gynecol Reprod Biol. Jan 15. 2004;112(1):84-8. Not eligible outcomes. [pmid: 14687746].
212 Aungst M, Wagner M. Foley balloon to tamponade bleeding in the retropubic space. Obstet Gynecol. Nov. 2003;102(5 Pt 1):1037-8. Case-reports. [pmid: 14672483].
213 Austin P, Spyropoulos E, Arango H, et al. The failed anti-incontinence mechanism: a flap valve or cecal wrap for surgical reconstruction. J Urol. May. 1997;157(5):1638-41. Case-series. [pmid: 9112494].
214 Austoni E, Guarneri A, Colombo F, et al. The new transperineal-prerectal approach in posterior urethroplasty. Arch Ital Urol Androl. Jun. 2005;77(2):122-4. Case-series. [pmid: 16146279].
215 Autry MG, Davis JW, Sanders R. Type III stress urinary incontinence: response to interdisciplinary pelvic physiotherapy. Urol Nurs. Aug. 2002;22(4):251-5. Case-reports. [pmid: 12242897].
216 Auwad W, Bombieri L, Adekanmi O, et al. The development of pelvic organ prolapse after colposuspension: a prospective, long-term follow-up study on the prevalence and predisposing factors. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):389-94. Case-series. [pmid: 16249832].
217 Avant OL, Jones JA, Beck H, et al. New method to improve treatment outcomes for radical prostatectomy. Urology. Oct 1. 2000;56(4):658-62. Case-series. [pmid: 11018627].
218 Averink M, Melein L, Duker PC. Establishing diurnal bladder control with the response restriction method: extended study on its effectiveness. Res Dev Disabil. Mar–Apr. 2005;26(2):143-51. Not eligible outcomes. [pmid: 15590245].
219 Awad RA. Biofeedback treatment of fecal incontinence incorporating a mental variable without instrumentation: a prospective pilot study in Hispanic population. Acta Gastroenterol Latinoam. 2005;35(4):230-7. Not eligible target population. [pmid: 16496855].
220 Awad SA, Al-Zahrani HM, Gajewski JB, et al. Long-term results and complications of augmentation ileocystoplasty for idiopathic urge incontinence in women. Br J Urol. Apr. 1998;81(4):569-73. Case-series. [pmid: 9598629].
221 Awad SA, Gajewski JB, Katz NO, et al. Final diagnosis and therapeutic implications of mixed symptoms of urinary incontinence in women. Urology. Apr. 1992;39(4):352-7. Not eligible outcomes. [pmid: 1557847].
222 Axelsen SM, Bek KM. Anterior vaginal wall repair using local anaesthesia. Eur J Obstet Gynecol Reprod Biol. Feb 10. 2004;112(2):214-6. Not eligible outcomes. [pmid: 14746962].
223 Axelsen SM, Petersen LK. Urogynaecological dysfunction after radical hysterectomy. Eur J Surg Oncol. May. 2006;32(4):445-9. Not eligible level of evidence. [pmid: 16516431].
224 Ayabaca SM, Zbar AP, Pescatori M. Anal continence after rectocele repair. Dis Colon Rectum. Jan. 2002;45(1):63-9. Case-series. [pmid: 11786766].
225 Ayan S, Gokce G, Kilicarslan H, et al. An unusual cause of incontinence: urethral coitus. Scand J Urol Nephrol. Jun. 2001;35(3):254. Case-reports. [pmid: 11487085].
226 Ayas S, Leblebici B, Sozay S, et al. The effect of abdominal massage on bowel function in patients with spinal cord injury. Am J Phys Med Rehabil. Dec. 2006;85(12):951-5. Not eligible outcomes. [pmid: 17117000].
227 Aygen EM, Ekmekcioglu O, Basbug M. The menopause and bladder weight. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):316-20. Not eligible exposure. [pmid: 10543340].
228 Ayhan A, Esin S, Guven S, et al. The Manchester operation for uterine prolapse. Int J Gynaecol Obstet. Mar. 2006;92(3):228-33. Not eligible exposure. [pmid: 16427641].
229 Baatenburg de Jong H, Admiraal H. Comparing cost per use of 3M Cavilon No Sting Barrier Film with zinc oxide oil in incontinent patients. J Wound Care. Oct. 2004;13(9):398-400. Not eligible outcomes. [pmid: 15517755].
230 Baba T, Koizumi M, Tanaka R, et al. Surgical management of genital prolapse: is chain cystourethrography useful for evaluating anatomical corrections and urinary symptoms after surgery?. J Obstet Gynaecol Res. Aug. 2000;26(4):289-94. Case-series. [pmid: 11049240].
231 Bachmann G. Urogenital ageing: an old problem newly recognized. Maturitas. Dec. 1995;22(Suppl):S1-S5. Review. [pmid: 8775770].
232 Bacon CG, Giovannucci E, Testa M, et al. The association of treatment-related symptoms with quality-of-life outcomes for localized prostate carcinoma patients. Cancer. Feb 1. 2002;94(3):862-71. Not eligible outcomes. [pmid: 11857323].
233 Bader P, Hugonnet CL, Burkhard FC, et al. Inefficient urethral milking secondary to urethral dysfunction as an additional risk factor for incontinence after radical prostatectomy. J Urol. Dec. 2001;166(6):2247-52. Case-series. [pmid: 11696745].
234 Badvie S, Andreyev HJ. Topical phenylephrine in the treatment of radiation-induced faecal incontinence. Clin Oncol (R Coll Radiol). Apr. 2005;17(2):122-6. Not eligible target population. [pmid: 15830575].
235 Baessler K, Bircher MD, Stanton SL. Pelvic floor dysfunction in women after pelvic trauma. Bjog. May. 2004;111(5):499-502. Case-series. [pmid: 15104618].
236 Baessler K, Hewson AD, Tunn R, et al. Severe mesh complications following intravaginal slingplasty. Obstet Gynecol. Oct. 2005;106(4):713-6. Case-series. [pmid: 16199626].
237 Baessler K, Stanton SL. Does Burch colposuspension cure coital incontinence?. Am J Obstet Gynecol. Apr. 2004;190(4):1030-3. Case-series. [pmid: 15118636].
238 Baeten CG, Geerdes BP, Adang EM, et al. Anal dynamic graciloplasty in the treatment of intractable fecal incontinence. N Engl J Med. Jun 15. 1995;332(24):1600-5. Case-series. [pmid: 7753138].
239 Baeten CG, Konsten J, Heineman E, et al. Dynamic graciloplasty for anal atresia. J Pediatr Surg. Jul. 1994;29(7):922-4. discussion 5. Case-series. [pmid: 7931971].
240 Baeten CG, Konsten J, Spaans F, et al. Dynamic graciloplasty for treatment of faecal incontinence. Lancet. Nov 9. 1991;338(8776):1163-5. Case-series. [pmid: 1682590].
241 Baeten CG, Uludag OO, Rongen MJ. Dynamic graciloplasty for fecal incontinence. Microsurgery. 2001;21(6):230-4. Not eligible target population. [pmid: 11746553].
242 Baffy G, Strate LL, Krnsky ML. Image of the month. Adherent, yellow exudate speckled with black spots in the distal two thirds of the esophagus. Diagnosis: This distinctive endoscopic image shows an acute necrotizing esophagitis, also known as the black esophagus. Gastroenterology. Feb. 2000;118(2):252-453. Not eligible exposure. [pmid: 10691371].
243 Bafghi A, Valerio L, Benizri EI, et al. Comparison between monofilament and multifilament polypropylene tapes in urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Oct 1. 2005;122(2):232-6. Not eligible exposure. [pmid: 16219524].
244 Bagi P, Biering-Sorensen F. Botulinum toxin A for treatment of neurogenic detrusor overactivity and incontinence in patients with spinal cord lesions. Scand J Urol Nephrol. 2004;38(6):495-8. Not eligible target population. [pmid: 15841785].
245 Bahl R, Strachan B, Murphy DJ. Pelvic floor morbidity at 3 years after instrumental delivery and cesarean delivery in the second stage of labor and the impact of a subsequent delivery. Am J Obstet Gynecol. Mar. 2005;192(3):789-94. Not eligible level of evidence. [pmid: 15746673].
246 Bai SW, Cho JM, Kwon HS, et al. The relationship between maximal urethral closure pressure and functional urethral length in anterior vaginal wall prolapse patients according to stage and age. Yonsei Med J. Jun 30. 2005;46(3):408-13. Case-series. [pmid: 15988814].
247 Bai SW, Chung KA, Rha KH, et al. Correlation between urodynamic test results, perineal ultrasound and degree of stress urinary incontinence. J Reprod Med. Sep. 2003;48(9):718-22. Not eligible target population. [pmid: 14562638].
248 Bai SW, Jeon JD, Chung KA, et al. The effectiveness of modified six-corner suspension in patients with paravaginal defect and stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):303-7. Case-series. [pmid: 12355290].
249 Bai SW, Jeon MJ, Kim JY, et al. Relationship between stress urinary incontinence and pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(4):256-60. discussion 60. Case-series. [pmid: 12189431].
250 Bai SW, Jung BH, Chung BC, et al. Relationship between urinary profile of the endogenous steroids and postmenopausal women with stress urinary incontinence. Neurourol Urodyn. 2003;22(3):198-205. Not eligible level of evidence. [pmid: 12707870].
251 Bai SW, Jung YW, Kwon HS, et al. The role of estrogen receptor, progesterone receptor and p53 in development of stress urinary incontinence. Yonsei Med J. Oct 31. 2004;45(5):885-90. Case-series. [pmid: 15515200].
252 Bai SW, Kang JY, Rha KH, et al. Relationship of urodynamic parameters and obesity in women with stress urinary incontinence. J Reprod Med. Jul. 2002;47(7):559-63. Not eligible level of evidence. [pmid: 12170533].
253 Bai SW, Kwon JY, Chung da J, et al. Differences in urodynamic study, perineal sonography and treatment outcome according to urethrovesical junction hypermobility in stress urinary incontinence. J Obstet Gynaecol Res. Apr. 2006;32(2):206-11. Case-series. [pmid: 16594926].
254 Bai SW, Lee JW, Shin JS, et al. The predictive values of various parameters in the diagnosis of stress urinary incontinence. Yonsei Med J. Apr 30. 2004;45(2):287-92. Not eligible level of evidence. [pmid: 15119001].
255 Bai SW, Park JH, Kim SK, et al. Analysis of the success rates of Burch colposuspension in relation to Valsalva leak-point pressure. J Reprod Med. Mar. 2005;50(3):189-92. Not eligible outcomes. [pmid: 15841931].
256 Bai SW, Roh JL, Kim JY, et al. Outcomes and surgical therapeutic index of Burch colposuspension in stress urinary incontinence. J Reprod Med. Feb. 2003;48(2):102-6. No associative hypothesis tested. [pmid: 12621793].
257 Baig LA, Karim SA. Age at menopause, and knowledge of and attitudes to menopause, of women in Karachi, Pakistan. J Br Menopause Soc. Jun. 2006;12(2):71-4. Not eligible outcomes. [pmid: 16776858].
258 Baik SH, Kim NK, Lee KY, et al. Hand-sewn coloanal anastomosis for distal rectal cancer: long-term clinical outcomes. J Gastrointest Surg. Jul–Aug. 2005;9(6):775-80. No associative hypothesis tested. [pmid: 15985232].
259 Baird AD, Frimberger D, Gearhart JP. Reconstructive lower urinary tract surgery in incontinent adolescents with exstrophy/epispadias complex. Urology. Sep. 2005;66(3):636-40. Not eligible target population. [pmid: 16140093].
260 Bakas P, Liapis A, Giner M, et al. Quality of life in relation to TVT procedure for the treatment of stress urinary incontinence. Acta Obstet Gynecol Scand. 2006;85(6):748-52. Case-series. [pmid: 16752270].
261 Bakas P, Liapis A, Karandreas A, et al. Pudendal nerve terminal motor latency in women with genuine stress incontinence and prolapse. Gynecol Obstet Invest. 2001;51(3):187-90. Case-series. [pmid: 11306907].
262 Bakas P, Liapis A, Salamalekis E, et al. Tension-free vaginal tape efficacy in relation to collagen quantity of pubocervical fascia. Gynecol Obstet Invest. 2004;57(3):149-52. Case-series. [pmid: 14709938].
263 Bakas PG, Liapis AE, Zervolea I, et al. mRNA assessment for procollagen production in women with genuine stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2004;15(6):429-31. discussion 31. Not eligible outcomes. [pmid: 15549263].
264 Baker DI, Bice TW. The influence of urinary incontinence on publicly financed home care services to low-income elderly people. Gerontologist. Jun. 1995;35(3):360-9. Not eligible exposure. [pmid: 7542620].
265 Bakke A, Myhr KM, Gronning M, et al. Bladder, bowel and sexual dysfunction in patients with multiple sclerosis—a cohort study. Scand J Urol Nephrol Suppl. 1996;179:61-6. Not eligible outcomes. [pmid: 8908666].
266 Bakx R, Sprangers MA, Oort FJ, et al. Development and validation of a colorectal functional outcome questionnaire. Int J Colorectal Dis. Mar. 2005;20(2):126-36. Not eligible outcomes. [pmid: 15449078].
267 Balash Y, Peretz C, Leibovich G, et al. Falls in outpatients with Parkinson's disease: frequency, impact and identifying factors. J Neurol. Nov. 2005;252(11):1310-5. Not eligible outcomes. [pmid: 15895303].
268 Bale S, Tebble N, Jones V, et al. The benefits of implementing a new skin care protocol in nursing homes. J Tissue Viability. Apr. 2004;14(2):44-50. Not eligible outcomes. [pmid: 15114926].
269 Balkrishnan R, Bhosle MJ, Camacho FT, et al. Predictors of medication adherence and associated health care costs in an older population with overactive bladder syndrome: a longitudinal cohort study. J Urol. Mar. 2006;175(3 Pt 1):1067-71. discussion 71–2. Not eligible outcomes. [pmid: 16469620].
270 Balmforth JR, Mantle J, Bidmead J, et al. A prospective observational trial of pelvic floor muscle training for female stress urinary incontinence. BJU Int. Oct. 2006;98(4):811-7. Not eligible target population. [pmid: 16978276].
271 Baloh RH, Jen JC, Kim G, et al. Chronic cough due to Thr124Met mutation in the peripheral myelin protein zero (MPZ gene). Neurology. May 25. 2004;62(10):1905-6. Case Reports. [pmid: 15159512].
272 Bamshad BR, Hadley HR, Ruckle HC, et al. Perfusion sphincterometry for objective evaluation of postprostatectomy intrinsic sphincter deficiency. Urology. May. 1999;53(5):968-73. Not eligible outcomes. [pmid: 10223491].
273 Bander NH. Initial results with slightly modified Kock pouch. Urology. Feb. 1991;37(2):100-5. Case-series. [pmid: 1992576].
274 Banerjee AK, Jehle EC, Kreis ME, et al. Prospective study of the proctographic and functional consequences of transanal endoscopic microsurgery. Br J Surg. Feb. 1996;83(2):211-3. Case-series. [pmid: 8689165].
275 Banerjee N, Deka D, Roy KK, et al. Vesicocervical fistula: an unusual presentation. Aust N Z J Obstet Gynaecol. May. 2000;40(2):219-20. Case-reports. [pmid: 10925916].
276 Banerjee S, Fusey SS. Vesicovaginal fistula with bladder eversion: a rare complication of third degree cervical descent. J Obstet Gynaecol Can. Feb. 2006;28(2):160-1. Case Reports. [pmid: 16643720].
277 Bang LM, Easthope SE, Perry CM. Transdermal oxybutynin: for overactive bladder. Drugs Aging. 2003;20(11):857-64. Review. [pmid: 12964892].
278 Bang RL. Penile oedema induced by continuous condom catheter use and mimicking keloid scar. Scand J Urol Nephrol. Sep. 1994;28(3):333-5. Case-seport. [pmid: 7817184].
279 Banks FC, Rao AR, Beatty J, et al. Erectile incontinence post radical prostatectomy. J R Soc Med. May. 2006;99(5):258-9. Case Reports. [pmid: 16672760]. [pmcid: 1457747].
280 Barabas G, Molstad S. No association between elevated post-void residual volume and bacteriuria in residents of nursing homes. Scand J Prim Health Care. Mar. 2005;23(1):52-6. Not eligible outcomes. [pmid: 16025875].
281 Barber MD, Kuchibhatla MN, Pieper CF, et al. Psychometric evaluation of 2 comprehensive condition-specific quality of life instruments for women with pelvic floor disorders. Am J Obstet Gynecol. Dec. 2001;185(6):1388-95. Not eligible outcomes. [pmid: 11744914].
282 Barber MD, Visco AG, Wyman JF, et al. Sexual function in women with urinary incontinence and pelvic organ prolapse. Obstet Gynecol. Feb. 2002;99(2):281-9. Not eligible outcomes. [pmid: 11814510].
283 Barber MD, Walters MD, Bump RC. Short forms of two condition-specific quality-of-life questionnaires for women with pelvic floor disorders (PFDI-20 and PFIQ-7). Am J Obstet Gynecol. Jul. 2005;193(1):103-13. Not eligible outcomes. [pmid: 16021067].
284 Barbic M, Kralj B. Effect of intra-abdominal position of the bladder neck and stability of its supporting structures on pressure transmission ratio after colposuspension. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(2):97-102. Case-series. [pmid: 10805267].
285 Barbic M, Kralj B, Cor A. Compliance of the bladder neck supporting structures: importance of activity pattern of levator ani muscle and content of elastic fibers of endopelvic fascia. Neurourol Urodyn. 2003;22(4):269-76. Not eligible outcomes. [pmid: 12808700].
286 Bardoux N, Leroi AM, Touchais JY, et al. Difficult defaecation and/or faecal incontinence as a presenting feature of neurologic disorders in four patients. Neurogastroenterol Motil. Mar. 1997;9(1):13-8. Case Reports. [pmid: 9058387].
287 Bardsley A. Promoting continence. Nurs Stand. Sep 25–Oct 1. 2002;17(2):112. Comment. [pmid: 12373973].
288 Bardsley M, Pather S, Neesham D, et al. Benign endocervical cystic glandular change mimicking minimal deviation adenocarcinoma of the cervix on magnetic resonance imaging: a case report. Aust N Z J Obstet Gynaecol. Aug. 2004;44(4):358-9. Not eligible exposure. [pmid: 15282014].
289 Barer DH. The influence of visual and tactile inattention on predictions for recovery from acute stroke. Q J Med. Jan. 1990;74(273):21-32. Not eligible outcomes. [pmid: 2326433].
290 Barisic G, Krivokapic Z, Markovic V, et al. The role of overlapping sphincteroplasty in traumatic fecal incontinence. Acta Chir Iugosl. 2000;47(4 Suppl 1):37-41. Case-series.
291 Barisic GI, Krivokapic ZV, Markovic VA, et al. Outcome of overlapping anal sphincter repair after 3 months and after a mean of 80 months. Int J Colorectal Dis. Jan. 2006;21(1):52-6. No associative hypothesis tested. [pmid: 15830204].
292 Barker J Jr, Wallner K, Merrick G. Gross hematuria after prostate brachytherapy. Urology. Feb. 2003;61(2):408-11. Not eligible level of evidence. [pmid: 12597957].
293 Barkin J, Corcos J, Radomski S, et al. A randomized, double-blind, parallel-group comparison of controlled- and immediate-release oxybutynin chloride in urge urinary incontinence. Clin Ther. Jul. 2004;26(7):1026-36. Not eligible exposure. [pmid: 15336467].
294 Barlas P, Hatzipapas J, Bias A, et al. Transvaginal colposuspension for the treatment of genuine stress incontinence combined with vaginal hysterectomy: a preliminary report. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(1):20-3. Case-series. [pmid: 8798082].
295 Barnes NM, Dmochowski RR, Park R, et al. Pubovaginal sling and pelvic prolapse repair in women with occult stress urinary incontinence: effect on postoperative emptying and voiding symptoms. Urology. Jun. 2002;59(6):856-60. Case-series. [pmid: 12031368].
296 Barnick CG, Cardozo LD. Denervation and re-innervation of the urethral sphincter in the aetiology of genuine stress incontinence: an electromyographic study. Br J Obstet Gynaecol. Aug. 1993;100(8):750-3. Not eligible outcomes. [pmid: 8399014].
297 Barranger E, Fritel X, Kadoch O, et al. Results of transurethral injection of silicone micro-implants for females with intrinsic sphincter deficiency. J Urol. Nov. 2000;164(5):1619-22. Case-series. [pmid: 11025718].
298 Barreto F, Dall'Oglio M, Srougi M. Recurrent vesicourethal stenosis after radical prostatectomy: how to treat it?. Int Braz J Urol. Nov–Dec. 2005;31(6):552-4. Case-series. [pmid: 16386124].
299 Barrett J. Treating faecal incontinence. Nurs Times. Aug 15–21. 1990;86(33):66-70. Comment. [pmid: 2385543].
300 Barrett JA, Brocklehurst JC, Kiff ES, et al. Rectal motility studies in faecally incontinent geriatric patients. Age Ageing. Sep. 1990;19(5):311-7. Not eligible outcomes. [pmid: 2251964].
301 Barrier A, Martel P, Gallot D, et al. Long-term functional results of colonic J pouch versus straight coloanal anastomosis. Br J Surg. Sep. 1999;86(9):1176-9. Case-series. [pmid: 10504373].
302 Barrington JW, Abdel-Fattah M, Arunkalaivanan AS, et al. Longitudinal study of Pelvicol pubovaginal slings using magnetic resonance imaging. J Obstet Gynaecol. Aug. 2004;24(5):542-6. Case-series. [pmid: 15369937].
303 Barrington JW, Arunkalaivanan AS, Swart M. Post-colposuspension syndrome following a tension-free vaginal tape procedure. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(3):187-8. Case Reports. [pmid: 12140714].
304 Barroso U Jr, Duel B, Barthold JS, et al. Orthotopic urethral substitution in female patients using the mitrofanoff principle. J Urol. Jan. 1999;161(1):251-3. Not eligible target population. [pmid: 10037417].
305 Barrows B, Bavendam T, Leach GE. Ectopically draining dysplastic kidney associated with genuine stress urinary incontinence: unusual combined cause of incontinence. Urology. Sep. 1992;40(3):283-5. Case-reports. [pmid: 1523758].
306 Bartels RH, van Overbeeke JJ. Lumbar cerebrospinal fluid drainage for symptomatic sacral nerve root cysts: an adjuvant diagnostic procedure and/or alternative treatment? Technical case report. Neurosurgery. Apr. 1997;40(4):861-4. discussion 4–5. Case-reports. [pmid: 9092864].
307 Barthet M, Bellon P, Abou E, et al. Anal endosonography for assessment of anal incontinence with a linear probe: relationships with clinical and manometric features. Int J Colorectal Dis. Mar. 2002;17(2):123-8. Not eligible outcomes. [pmid: 12014420].
308 Bartolo DC, Duthie GS. The physiological evaluation of operative repair for incontinence and prolapse. Ciba Found Symp. 1990;151:223-35. discussion 35–45. Case-series. [pmid: 2226061].
309 Bartram CI. Anal endosonography. Ann Gastroenterol Hepatol (Paris). Jun–Sep. 1992;28(4):185-9. Comment. [pmid: 1444185].
310 Bartram CI. Anal sphincter disorders. Gastrointest Endosc. Feb. 1996;43(2 Pt 2):S32-4. Comment. [pmid: 8929805].
311 Baskin LS. Case no. 2. Right-sided single system ureterocele. Tech Urol. Sep. 1998;4(3):152-3. Case report.
312 Bassiouny IE. Continent urinary reservoir in exstrophy/epispadias complex. Br J Urol. Nov. 1992;70(5):558-62. Not eligible target population. [pmid: 1467866].
313 Bastian PJ, Albers P, Haferkamp A, et al. Modified ureterosigmoidostomy (Mainz Pouch II) in different age groups and with different techniques of ureteric implantation. BJU Int. Aug. 2004;94(3):345-9. Case-series. [pmid: 15291865].
314 Bates TS, Wright MP, Gillatt DA. Prevalence and impact of incontinence and impotence following total prostatectomy assessed anonymously by the ICS-male questionnaire. Eur Urol. 1998;33(2):165-9. Case-series. [pmid: 9519358].
315 Bates-Jensen BM, Alessi CA, Al-Samarrai NR, et al. The effects of an exercise and incontinence intervention on skin health outcomes in nursing home residents. J Am Geriatr Soc. Mar. 2003;51(3):348-55. Not eligible outcomes. [pmid: 12588578].
316 Batignani G, Monaci I, Ficari F, et al. What affects continence after anterior resection of the rectum?. Dis Colon Rectum. Apr. 1991;34(4):329-35. Case-series. [pmid: 2007350].
317 Batislam E, Germiyanoglu C, Erol D. Simplification of laparoscopic extraperitoneal colposuspension: results of two-port technique. Int Urol Nephrol. 2000;32(1):47-51. Not eligible target population. [pmid: 11057772].
318 Baumgarten M, Margolis D, Gruber-Baldini AL, et al. Pressure ulcers and the transition to long-term care. Adv Skin Wound Care. Nov. 2003;16(6):299-304. Not eligible outcomes. [pmid: 14652516].
319 Baumgarten M, Margolis DJ, Localio AR, et al. Pressure ulcers among elderly patients early in the hospital stay. J Gerontol A Biol Sci Med Sci. Jul. 2006;61(7):749-54. Not eligible outcomes. [pmid: 16870639].
320 Bavbek M, Altinors MN, Caner HH, et al. Lumbar myxopapillary ependymoma mimicking neurofibroma. Spinal Cord. Aug. 2001;39(8):449-52. Case Reports. [pmid: 11512076].
321 Bayles KA, Tomoeda CK, Cruz RF, et al. Communication abilities of individuals with late-stage Alzheimer disease. Alzheimer Dis Assoc Disord. Jul–Sep. 2000;14(3):176-81. Not eligible exposure. [pmid: 10994659].
322 Bayliss V, Cherry M, Locke R, et al. Pathways for continence care: background and audit. Br J Nurs 2000 May 11–24; 9(9):590–2, 4, 6. No associative hypothesis tested
323 Bean JF, Kiely DK, Cairns KD, et al. Influence of poststroke urinary incontinence on disability: the nursing home setting. Am J Phys Med Rehabil. Mar. 2003;82(3):175-81. Not eligible outcomes. [pmid: 12595768].
324 Bear M, Dwyer JW, Benveneste D, et al. Home-based management of urinary incontinence: a pilot study with both frail and independent elders. J Wound Ostomy Continence Nurs. May. 1997;24(3):163-71. Case-series. [pmid: 9224024].
325 Bearz A, Giometto B, Freschi A, et al. Occult small cell lung cancer associated with paraneoplastic neurologic syndrome: case report. Tumori. Nov–Dec. 2001;87(6):447-50. Case-reports. [pmid: 11989604].
326 Beck RP, McCormick S, Nordstrom L. A 25-year experience with 519 anterior colporrhaphy procedures. Obstet Gynecol. Dec. 1991;78(6):1011-8. Not eligible level of evidence. [pmid: 1945199].
327 Beck SD, Koch MO. Spiral ileal neobladder substitution with orthotopic ureteral reimplantation: early results. Tech Urol. Sep. 2001;7(3):223-8. Case-series. [pmid: 11575519].
328 Becker C, Loy S, Sander S, et al. An algorithm to screen long-term care residents at risk for accidental falls. Aging Clin Exp Res. Jun. 2005;17(3):186-92. Not eligible outcomes. [pmid: 16110730].
329 Becker K, Enck P, Wilhelm K, et al. Colonic and anorectal dysfunction in a patient with the tethered cord syndrome. Am J Gastroenterol. Sep. 1994;89(9):1564-8. Case-reports. [pmid: 8079941].
330 Beckwith PS, Wolff BG, Frazee RC. Ileorectostomy in the older patient. Dis Colon Rectum. Apr. 1992;35(4):301-4. Case-series. [pmid: 1582348].
331 Beco J, Climov D, Bex M. Pudendal nerve decompression in perineology: a case series. BMC Surg. 2004;4:15. Case-series. [pmid: 15516268]. [pmcid: 529451].
332 Beco J, Leonard D, Lambotte R. Study of the artefacts induced by linear array transvaginal ultrasound scanning in urodynamics. World J Urol. 1994;12(6):329-32. Not eligible outcomes. [pmid: 7881471].
333 Beco J, Leonard D, Leonard F. Study of the female urethra's submucous vascular plexus by color Doppler. World J Urol. 1998;16(3):224-8. Not eligible outcomes. [pmid: 9666549].
334 Beddy P, Neary P, Eguare EI, et al. Electromyographic biofeedback can improve subjective and objective measures of fecal incontinence in the short term. J Gastrointest Surg. Jan. 2004;8(1):64-72. discussion 1–2. Case-series. [pmid: 14746837].
335 Beer-Gabel M, Teshler M, Barzilai N, et al. Dynamic transperineal ultrasound in the diagnosis of pelvic floor disorders: pilot study. Dis Colon Rectum. Feb. 2002;45(2):239-45. discussion 45–8. No associative hypothesis tested. [pmid: 11852339].
336 Beguin AM, Combes T, Lutzler P, et al. Health education improves older subjects' attitudes toward urinary incontinence and access to care: a randomized study in sheltered accommodation centers for the aged. J Am Geriatr Soc. Mar. 1997;45(3):391-2. Not eligible outcomes. [pmid: 9063297].
337 Beier-Holgersen R, Kirkeby LT, Nordling J. ‘Clam’ ileocystoplasty. Scand J Urol Nephrol. Mar. 1994;28(1):55-8. Case-series. [pmid: 8009194].
338 Beitz JM, Zuzelo PR. The lived experience of having a neobladder. West J Nurs Res. Apr. 2003;25(3):294-316. discussion 7–21. Case-series. [pmid: 12705113].
339 Beji NK, Yalcin O, Erkan HA. The effect of pelvic floor training on sexual function of treated patients. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):234-8. discussion 8. Not eligible outcomes. [pmid: 14530833].
340 Bellin P, Smith J, Poll W, et al. Results of a multicenter trial of the CapSure (Re/Stor) Continence shield on women with stress urinary incontinence. Urology. May. 1998;51(5):697-706. Not eligible target population. [pmid: 9610582].
341 Bellina J, Kelly R, Sartin B. A unique cause of unconscious urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):36-8. Case Reports. [pmid: 10207765].
342 Bellina M, Mari M, Ambu A, et al. Seminal monolateral nerve-sparing radical prostatectomy in selected patients. Urol Int. 2005;75(2):175-80. Not eligible exposure. [pmid: 16123574].
343 Belloli G, Campobasso P, Mercurella A. Neuropathic urinary incontinence in pediatric patients: management with artificial sphincter. J Pediatr Surg. Nov. 1992;27(11):1461-4. Not eligible target population. [pmid: 1479510].
344 Belmin J, Hervias Y, Avellano E, et al. Reliability of sampling urine from disposable diapers in elderly incontinent women. J Am Geriatr Soc. Nov. 1993;41(11):1182-6. Not eligible outcomes. [pmid: 8227891].
345 Belmonte-Montes C, Hagerman G, Vega-Yepez PA, et al. Anal sphincter injury after vaginal delivery in primiparous females. Dis Colon Rectum. Sep. 2001;44(9):1244-8. Not eligible outcomes. [pmid: 11584193].
346 Bemelmans BL, Kiemeney LA, Debruyne FM. Low-dose oxybutynin for the treatment of urge incontinence: good efficacy and few side effects. Eur Urol. Jun. 2000;37(6):709-13. Not eligible target population. [pmid: 10828672].
347 Ben Nagi J, Robinson D, Cardozo L, et al. Anatomical entrapment—an unusual cause of ‘urinary incontinence’. J Obstet Gynaecol. Sep. 2004;24(6):709-10. Case Reports. [pmid: 16147624].
348 Ben-Chaim J, Jeffs RD, Peppas DS, et al. Submucosal bladder neck injections of glutaraldehyde cross-linked bovine collagen for the treatment of urinary incontinence in patients with the exstrophy/epispadias complex. J Urol. Aug. 1995;154(2 Pt 2):862-4. Not eligible target population. [pmid: 7609199].
349 Ben-Chaim J, Jeffs RD, Reiner WG, et al. The outcome of patients with classic bladder exstrophy in adult life. J Urol. Apr. 1996;155(4):1251-2. Case-series. [pmid: 8632543].
350 Bender P. Deceptive distress in the elderly. Am J Nurs. Oct. 1992;92(10):28-32. Not eligible exposure. [pmid: 1466383].
351 Benderev TV. Anchor fixation and other modifications of endoscopic bladder neck suspension. Urology. Nov. 1992;40(5):409-18. Case-series. [pmid: 1441037].
352 Benedetti-Panici P, Zullo MA, Plotti F, et al. Long-term bladder function in patients with locally advanced cervical carcinoma treated with neoadjuvant chemotherapy and type 3–4 radical hysterectomy. Cancer. May 15. 2004;100(10):2110-7. Case-series. [pmid: 15139052].
353 Benezra V, Lambrou NC, Salom EM, et al. Conversion of an incontinent urinary conduit to a continent urinary reservoir (Miami Pouch). Gynecol Oncol. Sep. 2004;94(3):814-7. Case-reports. [pmid: 15350378].
354 Benhamou S, Laplanche A, Guillonneau B, et al. DNA adducts in normal bladder tissue and bladder cancer risk. Mutagenesis. Sep. 2003;18(5):445-8. Not eligible exposure. [pmid: 12960413].
355 Benizri EJ, Volpe P, Pushkar D, et al. A new vaginal procedure for cystocele repair and treatment of stress urinary incontinence. J Urol. Nov. 1996;156(5):1623-5. Case-series. [pmid: 8863553].
356 Bennett JK, Green BG, Foote JE, et al. Collagen injections for intrinsic sphincter deficiency in the neuropathic urethra. Paraplegia. Dec. 1995;33(12):697-700. Not eligible target population. [pmid: 8927407].
357 Bennett RG, Baran PJ, DeVone LV, et al. Low airloss hydrotherapy versus standard care for incontinent hospitalized patients. J Am Geriatr Soc. May. 1998;46(5):569-76. Not eligible outcomes. [pmid: 9588369].
358 Benoist S, Panis Y, Boleslawski E, et al. Functional outcome after coloanal versus low colorectal anastomosis for rectal carcinoma. J Am Coll Surg. Aug. 1997;185(2):114-9. Case-series. [pmid: 9249077].
359 Benoist S, Panis Y, Michot F, et al. Artificial sphincter with colonic reservoir for severe anal incontinence because of imperforate anus and short-bowel syndrome: report of a case. Dis Colon Rectum. Oct. 2005;48(10):1978-82. Case-reports. [pmid: 16229068].
360 Benoit RM, Naslund MJ, Cohen JK. A comparison of complications between ultrasound-guided prostate brachytherapy and open prostate brachytherapy. Int J Radiat Oncol Biol Phys. Jul 1. 2000;47(4):909-13. Not eligible outcomes. [pmid: 10863059].
361 Benson JT, McClellan E. The effect of vaginal dissection on the pudendal nerve. Obstet Gynecol. Sep. 1993;82(3):387-9. Not eligible outcomes. [pmid: 8355938].
362 Benson JT, Sumners JE, Pittman JS. Definition of normal female pelvic floor anatomy using ultrasonographic techniques. J Clin Ultrasound. Jun. 1991;19(5):275-82. Not eligible outcomes. [pmid: 1651343].
363 Bent AE, Foote J, Siegel S, et al. Collagen implant for treating stress urinary incontinence in women with urethral hypermobility. J Urol. Oct. 2001;166(4):1354-7. Not eligible target population. [pmid: 11547073].
364 Bent AE, Tutrone RT, McLennan MT, et al. Treatment of intrinsic sphincter deficiency using autologous ear chondrocytes as a bulking agent. Neurourol Urodyn. 2001;20(2):157-65. Not eligible target population. [pmid: 11170190].
365 Bentas W, Wolfram M, Jones J, et al. Robotic technology and the translation of open radical prostatectomy to laparoscopy: the early Frankfurt experience with robotic radical prostatectomy and one year follow-up. Eur Urol. Aug. 2003;44(2):175-81. Case-series. [pmid: 12875935].
366 Benvenuti F. Incontinence in the elderly. BJU Int. May. 2000;85(Suppl 3):79-80. discussion 1–2. Comment. [pmid: 11954203].
367 Benya R, Layden TJ, Mobarhan S. Diarrhea associated with tube feeding: the importance of using objective criteria. J Clin Gastroenterol. Apr. 1991;13(2):167-72. Not eligible outcomes. [pmid: 1903408].
368 Bercovich E, Manferrari F, Fiore F. A new device for self-adjustment of colposuspension. Eur Urol. 1994;26(2):189-92. Case-series. [pmid: 7957479].
369 Berger A, Tiret E, Parc R, et al. Excision of the rectum with colonic J pouch-anal anastomosis for adenocarcinoma of the low and mid rectum. World J Surg. May–Jun. 1992;16(3):470-7. Case-series. [pmid: 1589983].
370 Berger M, Wagner TH, Baker LC. Internet use and stigmatized illness. Soc Sci Med. Oct. 2005;61(8):1821-7. Not eligible outcomes. [pmid: 16029778].
371 Berglund AL, Eisemann M, Lalos A, et al. Social adjustment and spouse relationships among women with stress incontinence before and after surgical treatment. Soc Sci Med. Jun. 1996;42(11):1537-44. Case -Series. [pmid: 8771636].
372 Berglund AL, Eisemann M, Lalos A, et al. Predictive factors of the outcome of primary surgical treatment of stress incontinence in women. Scand J Urol Nephrol. Feb. 1997;31(1):49-55. No associative hypothesis tested. [pmid: 9060084].
373 Berglund AL, Fugl-Meyer KS. Sexual problems in women with urinary incontinence. A retrospective study of medical records. Scand J Caring Sci. 1991;5(1):13-6. Not eligible outcomes. [pmid: 2011667].
374 Bergman J, Robertson JR, Elia G. Effects of a magnetic field on pelvic floor muscle function in women with stress urinary incontinence. Altern Ther Health Med. May–Jun. 2004;10(3):70-2. Case-series.
375 Bergquist S. Pressure ulcer prediction in older adults receiving home health care: implications for use with the OASIS. Adv Skin Wound Care. May–Jun. 2003;16(3):132-9. Not eligible exposure. [pmid: 12789035].
376 Bergstrom K, Carlsson CP, Lindholm C, et al. Improvement of urge- and mixed-type incontinence after acupuncture treatment among elderly women - a pilot study. J Auton Nerv Syst. Mar 15. 2000;79(23):173-80. Not eligible target population. [pmid: 10699649].
377 Berkelmans I, Heresbach D, Leroi AM, et al. Perineal descent at defecography in women with straining at stool: a lack of specificity or predictive value for future anal incontinence?. Eur J Gastroenterol Hepatol. Jan. 1995;7(1):75-9. Case-series. [pmid: 7866816].
378 Berkelmans I, Leroi AM, Weber J, et al. Faecal incontinence with transitory absence of anal contraction in two sexually or physically abused women. Eur J Gastroenterol Hepatol. Mar. 1996;8(3):235-8. Case-Reports. [pmid: 8724023].
379 Berkowitz LR. Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 20-2004. A 46-year-old woman with pelvic-floor relaxation after a second vaginal delivery. N Engl J Med. Jun 24. 2004;350(26):2699-706. Case-reports. [pmid: 15215487].
380 Berlowitz DR, Brand HK, Perkins C. Geriatric syndromes as outcome measures of hospital care: can administrative data be used?. J Am Geriatr Soc. Jun. 1999;47(6):692-6. Not eligible outcomes. [pmid: 10366168].
381 Berlowitz DR, Brandeis GH, Morris JN, et al. Deriving a risk-adjustment model for pressure ulcer development using the Minimum Data Set. J Am Geriatr Soc. Jul. 2001;49(7):866-71. Not eligible outcomes. [pmid: 11527476].
382 Berman CJ, Kreder KJ. Comparative cost analysis of collagen injection and fascia lata sling cystourethropexy for the treatment of type III incontinence in women [ssee comments]. J Urol. Jan. 1997;157(1):122-4. Not eligible outcomes. [pmid: 8976231].
383 Berman IR. Sutureless laparoscopic rectopexy for procidentia. Technique and implications. Dis Colon Rectum. Jul. 1992;35(7):689-93. Case Reports. [pmid: 1535309].
384 Bernardi C, Favetta U, Pescatori M. Autologous fat injection for treatment of fecal incontinence: manometric and echographic assessment. Plast Reconstr Surg. Oct. 1998;102(5):1626-8. Case Reports. [pmid: 9774022].
385 Berned Muller E, Nordwall A, von Wendt L. The influence of scoliosis brace treatment on function in children with myelomeningocele. Acta Paediatr. Nov. 1992;81(11):925-8. Not eligible target population. [pmid: 1467616].
386 Bernier F, Harris L. Treating stress incontinence with the bladder neck support prosthesis. Urol Nurs. Mar. 1995;15(1):5-9. Not eligible exposure. [pmid: 7792623].
387 Bernstein IT, Bennicke K, Rordam P, et al. Bricker's ileal conduit urinary diversion with a simple non-refluxing uretero ileal anastomosis. Scand J Urol Nephrol. 1991;25(1):29-33. Case-series. [pmid: 2047769].
388 Berry AR, Souter RG, Campbell WB, et al. Endoscopic transanal resection of rectal tumours—a preliminary report of its use. Br J Surg. Feb. 1990;77(2):134-7. Case-series. [pmid: 1690587].
389 Besarani D, Amoroso P, Kirby R. Bladder neck contracture after radical retropubic prostatectomy. BJU Int. Dec. 2004;94(9):1245-7. Not eligible outcomes. [pmid: 15610098].
390 Bezerra CA, Rodrigues AO, Seo AL, et al. Laparoscopic Burch surgery: is there any advantage in relation to open approach?. Int Braz J Urol. May–Jun. 2004;30(3):230-6. Case-series. [pmid: 15689257].
391 Bezerra CA, Sadi MV. Comparison of vaginal wall sling and modified vaginal wall sling for stress urinary incontinence. Sao Paulo Med J. May 4. 2000;118(3):63-8. Not eligible target population. [pmid: 10810330].
392 Bharucha AE, Fletcher JG, Harper CM, et al. Relationship between symptoms and disordered continence mechanisms in women with idiopathic faecal incontinence. Gut. Apr. 2005;54(4):546-55. Not eligible level of evidence. [pmid: 15753542]. [pmcid: 1774446].
393 Bharucha AE, Fletcher JG, Seide B, et al. Phenotypic variation in functional disorders of defecation. Gastroenterology. May. 2005;128(5):1199-210. Not eligible target population. [pmid: 15887104].
394 Bharucha AE, Locke GR 3rd, Seide BM, et al. A new questionnaire for constipation and faecal incontinence. Aliment Pharmacol Ther. Aug 1. 2004;20(3):355-64. Not eligible outcomes. [pmid: 15274673].
395 Bharucha AE, Zinsmeister AR, Locke GR, et al. Symptoms and quality of life in community women with fecal incontinence. Clin Gastroenterol Hepatol. Aug. 2006;4(8):1004-9. Not eligible level of evidence. [pmid: 16630766].
396 Bhattacharya S, Mollison J, Pinion S, et al. A comparison of bladder and ovarian function two years following hysterectomy or endometrial ablation. Br J Obstet Gynaecol. Sep. 1996;103(9):898-903. Not eligible level of evidence. [pmid: 8813310].
397 Bianco FJ Jr, Riedel ER, Begg CB, et al. Variations among high volume surgeons in the rate of complications after radical prostatectomy: further evidence that technique matters. J Urol. Jun. 2005;173(6):2099-103. Not eligible exposure. [pmid: 15879851]. [pmcid: 1855289].
398 Bidair M, Tiechman JM, Brodak PP, et al. Transrectal ultrasound urodynamics. Urology. Dec. 1993;42(6):640-4. discussion 4–5. Case-series. [pmid: 8256397].
399 Bidmead J, Cardozo L, McLellan A, et al. A comparison of the objective and subjective outcomes of colposuspension for stress incontinence in women. Bjog. Apr. 2001;108(4):408-13. Case-series. [pmid: 11305549].
400 Bielefeldt K, Enck P, Erckenbrecht JF. Sensory and motor function in the maintenance of anal continence. Dis Colon Rectum. Aug. 1990;33(8):674-8. Not eligible outcomes. [pmid: 2376223].
401 Bigio EH, Weiner MF, Bonte FJ, et al. Familial dementia due to adult polyglucosan body disease?. Clin Neuropathol. Jul–Aug. 1997;16(4):227-34. Case-reports. [pmid: 9266150].
402 Bignell V. Alleviating the distress of urinary incontinence. Community Nurse 1999 Oct; 5(9):19–20, 2. Comment
403 Bilali S, Pfeifer J. Anorectal manometry: are fatigue rate and fatigue rate index of any clinical importance?. Tech Coloproctol. Dec. 2005;9(3):225-8. Not eligible level of evidence. [pmid: 16328124].
404 Billington A. Incontinence in older women. Elder Care. Nov. 1999;11(8):32-3. Comment. [pmid: 10614306].
405 Bingol A, Yucemen N, Meco O. Medically treated intraspinal “Brucella” granuloma. Surg Neurol. Dec. 1999;52(6):570-6. Case-Reports. [pmid: 10660022].
406 Binnie F. Incontinent patients take part in test. N Z Nurs J. Feb. 1993;86(1):12-4. No associative hypothesis tested. [pmid: 8455878].
407 Binnie NR, Kawimbe BM, Papachrysostomou M, et al. Use of the pudendo-anal reflex in the treatment of neurogenic faecal incontinence. Gut. Sep. 1990;31(9):1051-5. Case-series. [pmid: 2170249]. [pmcid: 1378668].
408 Binstock MA, Semrad N, Dubow L, et al. Combined vesicovaginal-ureterovaginal fistulas associated with a vaginal foreign body. Obstet Gynecol. Nov. 1990;76(5 Pt 2):918-21. Case Reports. [pmid: 2216257].
409 Birnbaum EH, Dreznik Z, Myerson RJ, et al. Early effect of external beam radiation therapy on the anal sphincter: a study using anal manometry and transrectal ultrasound. Dis Colon Rectum. Aug. 1992;35(8):757-61. Case-series. [pmid: 1643999].
410 Birnbaum EH, Myerson RJ, Fry RD, et al. Chronic effects of pelvic radiation therapy on anorectal function. Dis Colon Rectum. Sep. 1994;37(9):909-15. Case-series. [pmid: 8076491].
411 Birnbaum EH, Stamm L, Rafferty JF, et al. Pudendal nerve terminal motor latency influences surgical outcome in treatment of rectal prolapse. Dis Colon Rectum. Nov. 1996;39(11):1215-21. Case-series. [pmid: 8918427].
412 Birnbaum H, Leong S, Kabra A. Lifetime medical costs for women: cardiovascular disease, diabetes, and stress urinary incontinence. Womens Health Issues. Nov–Dec. 2003;13(6):204-13. Not eligible outcomes. [pmid: 14675789].
413 Bishop KR, Dougherty M, Mooney R, et al. Effects of age, parity, and adherence on pelvic muscle response to exercise. J Obstet Gynecol Neonatal Nurs. Sep–Oct. 1992;21(5):401-6. Not eligible outcomes.
414 Bittorf B, Stadelmaier U, Gohl J, et al. Functional outcome after intersphincteric resection of the rectum with coloanal anastomosis in low rectal cancer. Eur J Surg Oncol. Apr. 2004;30(3):260-5. Case-series. [pmid: 15028306].
415 Bittorf B, Stadelmaier U, Merkel S, et al. Does anastomotic leakage affect functional outcome after rectal resection for cancer?. Langenbecks Arch Surg. Feb. 2003;387(1112):406-10. Case-series. [pmid: 12607120].
416 Bjelic-Radisic V, Dorfer M, Greimel E, et al. Quality of life and continence 1 year after the tension-free vaginal tape operation. Am J Obstet Gynecol. Dec. 2006;195(6):1784-8. Case-series. [pmid: 17132481].
417 Bjelic-Radisic V, Dorfer M, Tamussino K, et al. Psychometric properties and validation of the German-language King's Health Questionnaire in women with stress urinary incontinence. Neurourol Urodyn. 2005;24(1):63-8. Not eligible outcomes. [pmid: 15578627].
418 Bjork J, Akerbrant H, Iselius L, et al. Outcome of primary and secondary ileal pouch-anal anastomosis and ileorectal anastomosis in patients with familial adenomatous polyposis. Dis Colon Rectum. Jul. 2001;44(7):984-92. Not eligible target population. [pmid: 11496079].
419 Bjornland K, Diseth TH, Emblem R. Long-term functional, manometric, and endosonographic evaluation of patients operated upon with the Duhamel technique. Pediatr Surg Int. Jan. 1998;13(1):24-8. Case-series. [pmid: 9391199].
420 Bjornsdottir LT, Geirsson RT, Jonsson PV. Urinary incontinence and urinary tract infections in octogenarian women. Acta Obstet Gynecol Scand. Jan. 1998;77(1):105-9. Not eligible level of evidence. [pmid: 9492729].
421 Black N, Griffiths J, Pope C. Development of a symptom severity index and a symptom impact index for stress incontinence in women. Neurourol Urodyn. 1996;15(6):630-40. Not eligible outcomes. [pmid: 8916115].
422 Black N, Griffiths J, Pope C, et al. Impact of surgery for stress incontinence on morbidity: cohort study. BMJ. Dec 6. 1997;315(7121):1493-8. No associative hypothesis tested. [pmid: 9420489]. [pmcid: 2127933].
423 Black NA, Bowling A, Griffiths JM, et al. Impact of surgery for stress incontinence on the social lives of women. Br J Obstet Gynaecol. Jun. 1998;105(6):605-12. Case-series. [pmid: 9647150].
424 Black NA, Griffiths JM, Pope C, et al. Sociodemographic and symptomatic characteristics of women undergoing stress incontinence surgery in the UK. Br J Urol. Dec. 1996;78(6):847-55. Not eligible target population. [pmid: 9014707].
425 Black SA, Goodwin JS, Markides KS. The association between chronic diseases and depressive symptomatology in older Mexican Americans. J Gerontol A Biol Sci Med Sci. May. 1998;53(3):M188-94. Not eligible outcomes. [pmid: 9597050].
426 Blair KA, White N. Are older women offered adequate health care?. J Gerontol Nurs. Oct. 1998;24(10):39-44. Not eligible outcomes. [pmid: 9923241].
427 Blaivas JG, Groutz A. Bladder outlet obstruction nomogram for women with lower urinary tract symptomatology. Neurourol Urodyn. 2000;19(5):553-64. Not eligible outcomes. [pmid: 11002298].
428 Blaivas JG, Jacobs BZ. Pubovaginal fascial sling for the treatment of complicated stress urinary incontinence. J Urol. Jun. 1991;145(6):1214-8. Case-series. [pmid: 2033696].
429 Blaivas JG, Weiss JP, Jones M. The pathophysiology of lower urinary tract symptoms after brachytherapy for prostate cancer. BJU Int. Dec. 2006;98(6):1233-7. discussion 7. Case-series. [pmid: 17125481].
430 Bland DR, Earle BB, Vitolins MZ, et al. Use of the Pelvic Organ Prolapse staging system of the International Continence Society, American Urogynecologic Society, and Society of Gynecologic Surgeons in perimenopausal women. Am J Obstet Gynecol. Dec. 1999;181(6):1324-7. discussion 7–8. Not eligible level of evidence. [pmid: 10601907].
431 Blander DS, Carpiniello VL, Harryhill JF, et al. Extraperitoneal laparoscopic urethropexy with Marlex mesh. Urology. May. 1999;53(5):985-9. Not eligible target population. [pmid: 10223494].
432 Blander DS, Zimmern PE. Cadaveric fascia lata sling: analysis of five recent adverse outcomes. Urology. Oct 1. 2000;56(4):596-9. Case-series. [pmid: 11018613].
433 Blanes L, Pinto Rde C, Santos VL. Urinary incontinence knowledge and attitudes in Sao Paulo. Ostomy Wound Manage. Dec. 2001;47(12):43-51. Not eligible level of evidence. [pmid: 11889727].
434 Blank LE, Gonzalez Gonzalez D, de Reijke TM, et al. Brachytherapy with transperineal (125)Iodine seeds for localized prostate cancer. Radiother Oncol. Dec. 2000;57(3):307-13. Not eligible level of evidence. [pmid: 11104891].
435 Bliss DP Jr, Tapper D, Anderson JM, et al. Does posterior sagittal anorectoplasty in patients with high imperforate anus provide superior fecal continence?. J Pediatr Surg. Jan. 1996;31(1):26-30. discussion -2. Not eligible target population. [pmid: 8632281].
436 Bliss DZ, Fischer LR, Savik K. Managing fecal incontinence: self-care practices of older adults. J Gerontol Nurs. Jul. 2005;31(7):35-44. Not eligible outcomes. [pmid: 16047958].
437 Bliss DZ, Johnson S, Savik K, et al. Fecal incontinence in hospitalized patients who are acutely ill. Nurs Res. Mar–Apr. 2000;49(2):101-8. Not eligible target population. [pmid: 10768587].
438 Bliss DZ, McLaughlin J, Jung HJ, et al. Comparison of the nutritional composition of diets of persons with fecal incontinence and that of age- and gender-matched controls. J Wound Ostomy Continence Nurs 2000 Mar; 27(2):90–1, 3–7. Not eligible outcomes
439 Bliss DZ, Savik K, Harms S, et al. Prevalence and correlates of perineal dermatitis in nursing home residents. Nurs Res. Jul–Aug. 2006;55(4):243-51. Not eligible outcomes. [pmid: 16849976].
440 Bliss DZ, Savik K, Jung H, et al. Comparison of subjective classification of stool consistency and stool water content. J Wound Ostomy Continence Nurs. May. 1999;26(3):137-41. Not eligible outcomes. [pmid: 10711123].
441 Bliwise DL, Adelman CL, Ouslander JG. Polysomnographic correlates of spontaneous nocturnal wetness episodes in incontinent geriatric patients. Sleep. Feb 1. 2004;27(1):153-7. Case-series. [pmid: 14998253].
442 Block CA, Cooper CS, Hawtrey CE. Long-term efficacy of periurethral collagen injection for the treatment of urinary incontinence secondary to myelomeningocele. J Urol. Jan. 2003;169(1):327-9. Not eligible target population. [pmid: 12478183].
443 Blonski J. Is tolterodine (Detrol) or oxybutynin (Ditropan) the best for treatment of urge urinary incontinence?. J Fam Pract. Dec. 2001;50(12):1017. Review. [pmid: 11742595].
444 Bo K. Reproducibility of instruments designed to measure subjective evaluation of female stress urinary incontinence. Scand J Urol Nephrol. Mar. 1994;28(1):97-100. [pmid: 8009197].
445 Bo K. Pelvic floor muscle strength and response to pelvic floor muscle training for stress urinary incontinence. Neurourol Urodyn. 2003;22(7):654-8. No associative hypothesis tested. [pmid: 14595609].
446 Bo K, Borgen JS. Prevalence of stress and urge urinary incontinence in elite athletes and controls. Med Sci Sports Exerc. Nov. 2001;33(11):1797-802. Not eligible level of evidence. [pmid: 11689727].
447 Bo K, Finckenhagen HB. Vaginal palpation of pelvic floor muscle strength: inter-test reproducibility and comparison between palpation and vaginal squeeze pressure. Acta Obstet Gynecol Scand. Oct. 2001;80(10):883-7. Not eligible outcomes. [pmid: 11580731].
448 Bo K, Finckenhagen HB. Is there any difference in measurement of pelvic floor muscle strength in supine and standing position?. Acta Obstet Gynecol Scand. Dec. 2003;82(12):1120-4. Not eligible outcomes. [pmid: 14616257].
449 Bo K, Maanum M. Does vaginal electrical stimulation cause pelvic floor muscle contraction? A pilot study. Scand J Urol Nephrol Suppl. 1996;179:39-45. Not eligible outcomes. [pmid: 8908663].
450 Boccasanta P, Rosati R, Venturi M, et al. Surgical treatment of complete rectal prolapse: results of abdominal and perineal approaches. J Laparoendosc Adv Surg Tech A. Jun. 1999;9(3):235-8. Case-series. [pmid: 10414538].
451 Boccasanta P, Venturi M, Reitano MC, et al. Laparotomic vs. laparoscopic rectopexy in complete rectal prolapse. Dig Surg. 1999;16(5):415-9. Case-series. [pmid: 10567804].
452 Boccasanta P, Venturi M, Stuto A, et al. Stapled transanal rectal resection for outlet obstruction: a prospective, multicenter trial. Dis Colon Rectum. Aug. 2004;47(8):1285-96. discussion 96–7. Not eligible target population. [pmid: 15484341].
453 Bochner BH, Figueroa AJ, Skinner EC, et al. Salvage radical cystoprostatectomy and orthotopic urinary diversion following radiation failure. J Urol. Jul. 1998;160(1):29-33. Case-series. [pmid: 9628599].
454 Bodden-Heidrich R, Beckmann MW, Libera B, et al. Psychosomatic aspects of urinary incontinence. Arch Gynecol Obstet. 1999;262(34):151-8. Not eligible outcomes. [pmid: 10326634].
455 Boemers TM, Ludwikowski B, Forstner R, et al. Dynamic magnetic resonance imaging of the pelvic floor in children and adolescents with vesical and anorectal malformations. J Pediatr Surg. Jul. 2006;41(7):1267-71. Not eligible target population. [pmid: 16818061].
456 Bogner HR, Gallo JJ, Swartz KL, et al. Anxiety disorders and disability secondary to urinary incontinence among adults over age 50. Int J Psychiatry Med. 2002;32(2):141-54. Not eligible level of evidence. [pmid: 12269595].
457 Bollard RC, Gardiner A, Duthie GS, et al. Anal sphincter injury, fecal and urinary incontinence: a 34-year follow-up after forceps delivery. Dis Colon Rectum. Aug. 2003;46(8):1083-8. Not eligible level of evidence. [pmid: 12907903].
458 Bombier L, Freeman RM, Perkins EP, et al. Why do women have voiding dysfunction and de novo detrusor instability after colposuspension?. Bjog. Apr. 2002;109(4):402-12. Prospective, observational study <100. [pmid: 12013161].
459 Bombieri L, Freeman RM. Recurrence of stress incontinence after vault suspension: can it be prevented?. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(1):58-60. Case Reports. [pmid: 9657181].
460 Bombieri L, Freeman RM, Perkins EP, et al. Objective assessment of bladder neck elevation and urethral compression at colposuspension. Bjog. Apr. 2002;109(4):395-401. Not eligible exposure. [pmid: 12013160].
461 Bond C, Youngson G, MacPherson I, et al. Anal plugs for the management of fecal incontinence in children and adults: a randomized control trial. J Clin Gastroenterol. Jan. 2007;41(1):45-53. Not eligible target population. [pmid: 17198065].
462 Bonetti TR, Erpelding A, Pathak LR. Listening to “felt needs”: investigating genital prolapse in western Nepal. Reprod Health Matters. May. 2004;12(23):166-75. Not eligible outcomes. [pmid: 15242225].
463 Bonnet P, Waltregny D, Reul O, et al. Transobturator vaginal tape inside out for the surgical treatment of female stress urinary incontinence: anatomical considerations. J Urol. Apr. 2005;173(4):1223-8. Case-series. [pmid: 15758757].
464 Bonney W. Voiding dysfunction and incontinence. Iowa Med. Apr. 1992;82(4):173-5. Case Reports. [pmid: 1618614].
465 Bonney WW, Gupta S, Hunter DR, et al. Bladder dysfunction in schizophrenia. Schizophr Res. Jun 20. 1997;25(3):243-9. Not eligible outcomes. [pmid: 9264179].
466 Bonvini RF, Camezind E. Electrocardiogram artefacts caused by an abdominal electrostimulator. Med J Aust. Oct 18. 2004;181(8):455. Case-Reports. [pmid: 15612084].
467 Borchers H, Kirschner-Hermanns R, Brehmer B, et al. Permanent 125I-seed brachytherapy or radical prostatectomy: a prospective comparison considering oncological and quality of life results. BJU Int. Oct. 2004;94(6):805-11. Not eligible level of evidence. [pmid: 15476513].
468 BorelloFrance D, Burgio KL, Richter HE, et al. Fecal and urinary incontinence in primiparous women. Obstetrics and gynecology. Oct. 2006;108(4):863-72. Not eligible level of evidence. [pmid: 17012447].
469 Borello-France DF, Handa VL, Brown MB, et al. Pelvic-floor muscle function in women with pelvic organ prolapse. Phys Ther. Apr. 2007;87(4):399-407. Case-series. [pmid: 17341510].
470 Borenstein R, Elchalal U, Goldchmit R, et al. The importance of the endopelvic fascia repair during vaginal hysterectomy. Surg Gynecol Obstet. Dec. 1992;175(6):551-4. Not eligible target population. [pmid: 1448737].
471 Borjesson L, Oresland T, Hulten L. The failed pelvic pouch: conversion to a continent ileostomy. Tech Coloproctol. Aug. 2004;8(2):102-5. Case-series. [pmid: 15309647].
472 Borrie MJ, Valiquette L. Managing adults with urinary incontinence. Clinical practice guidelines. Can Fam Physician. Jan. 2002;48:114-6. Guideline. [pmid: 11852599]. [pmcid: 2213931].
473 Borstad E, Skrede M, Rud T. Failure to predict and attempts to explain urinary stress incontinence following vaginal repair in continent women by using a modified lateral urethrocystography. Acta Obstet Gynecol Scand. 1991;70(6):501-6. Case-series. [pmid: 1842676].
474 Bortel DT. Candida osteomyelitis pubis following a Marshall-Marchetti procedure. Orthopedics. Dec. 1993;16(12):1353-5. Case Reports. [pmid: 8108286].
475 Borup K, Nielsen JB. Results in 32 women operated for genuine stress incontinence with the pubovaginal sling procedure ad modum Ed McGuire. Scand J Urol Nephrol. 2002;36(2):128-33. Case-series. [pmid: 12028686].
476 Bosch JL, Groen J. Sacral (S3) segmental nerve stimulation as a treatment for urge incontinence in patients with detrusor instability: results of chronic electrical stimulation using an implantable neural prosthesis. J Urol. Aug. 1995;154(2 Pt 1):504-7. Not eligible target population. [pmid: 7609117].
477 Bosch JL, Groen J. Neuromodulation: urodynamic effects of sacral (S3) spinal nerve stimulation in patients with detrusor instability or detrusor hyperflexia. Behav Brain Res. May. 1998;92(2):141-50. Case-series. [pmid: 9638956].
478 Bosch JL, Groen J. Sacral nerve neuromodulation in the treatment of patients with refractory motor urge incontinence: long-term results of a prospective longitudinal study. J Urol. Apr. 2000;163(4):1219-22. Not eligible target population. [pmid: 10737501].
479 Bosch JL, Klijn AJ, Schroder FH, et al. The artificial urinary sphincter in 86 patients with intrinsic sphincter deficiency: satisfactory actuarial adequate function rates. Eur Urol. Aug. 2000;38(2):156-60. Case-series. [pmid: 10895006].
480 Bose CK, Basu A, Kanjilal S, et al. Giant supratrigonal vesicocervicovaginal fistula—a case report. MedGenMed. 2005;7(4):74. Case report. [pmid: 16614696].
481 Botros SM, Abramov Y, Goldberg RP, et al. Detrusor overactivity and urge urinary incontinence [corrected] following midurethral versus bladder sling procedures. Am J Obstet Gynecol. Dec. 2005;193(6):2144-8. Case-series. [pmid: 16325631].
482 Botros SM, Abramov Y, Miller JJ, et al. Effect of parity on sexual function: an identical twin study. Obstet Gynecol. Apr. 2006;107(4):765-70. Not eligible outcomes. [pmid: 16582110].
483 Botros SM, Miller JJ, Goldberg RP, et al. Detrusor overactivity and urge urinary incontinence following trans obturator versus midurethral slings. Neurourol Urodyn. 2007;26(1):42-5. Case-series. [pmid: 17149712].
484 Bottin A, Cescon C, Nowakowski M, et al. Non-invasive assessment of the gracilis muscle by means of surface electromyography electrode arrays. J Surg Res. Aug. 2006;134(2):265-9. Not eligible outcomes. [pmid: 16580693].
485 Botto H, Sebe P, Molinie V, et al. Prostatic capsule- and seminal-sparing cystectomy for bladder carcinoma: initial results for selected patients. BJU Int. Nov. 2004;94(7):1021-5. Case-series. [pmid: 15541120].
486 Bouchoucha M, Devroede G, Faye A, et al. Importance of colonic transit evaluation in the management of fecal incontinence. Int J Colorectal Dis. Nov. 2002;17(6):412-7. discussion 8–9. Case-series. [pmid: 12355217].
487 Boulet MJ, Oddens BJ, Lehert P, et al. Climacteric and menopause in seven South-east Asian countries. Maturitas. Oct. 1994;19(3):157-76. Not eligible level of evidence. [pmid: 7799822].
488 Bourne A. Promoting continence in nursing homes: responding to government guidelines. Nurs Older People. Nov. 2003;15(8):14-6. Comment.
489 Bours GJ, De Laat E, Halfens RJ, et al. Prevalence, risk factors and prevention of pressure ulcers in Dutch intensive care units. Results of a cross-sectional survey. Intensive Care Med. Oct. 2001;27(10):1599-605. Not eligible outcomes. [pmid: 11685300].
490 Bowles J, Brooks T, Hayes-Reams P, et al. Frailty, family, and church support among urban African American elderly. J Health Care Poor Underserved. Feb. 2000;11(1):87-99. Not eligible outcomes. [pmid: 10778045].
491 Boy S, Reitz A, Curt A, et al. A case of undiagnosed tethered cord syndrome aggravated by transurethral prostate resection. Nat Clin Pract Urol. Apr. 2005;2(4):199-204. quiz 1 p following Case report. [pmid: 16474763].
492 Boyd BG, McCallum SW, Lewis RW, et al. Assessment of patient concern and adequacy of informed consent regarding infertility resulting from prostate cancer treatment. Urology. Oct. 2006;68(4):840-4. Not eligible outcomes. [pmid: 17070364].
493 Boyd SD, Lieskovsky G, Skinner DG. Kock pouch bladder replacement. Urol Clin North Am. Nov. 1991;18(4):641-8. Case-series. [pmid: 1949397].
494 Boyington AR, Wildemuth BM, Dougherty MC, et al. Development of a computer-based system for continence health promotion. Nurs Outlook. Sep–Oct. 2004;52(5):241-7. Not eligible exposure. [pmid: 15499313].
495 Boyles SH, Weber AM, Meyn L. Procedures for urinary incontinence in the United States, 1979-1997. Am J Obstet Gynecol. Jul. 2003;189(1):70-5. Not eligible outcomes. [pmid: 12861141].
496 Boyles SH, Weber AM, Meyn L. Procedures for pelvic organ prolapse in the United States, 1979-1997. Am J Obstet Gynecol. Jan. 2003;188(1):108-15. Not eligible exposure. [pmid: 12548203].
497 Boyles SH, Weber AM, Meyn L. Ambulatory procedures for urinary incontinence in the United States, 1994-1996. Am J Obstet Gynecol. Jan. 2004;190(1):33-6. Not eligible level of evidence. [pmid: 14749631].
498 Bozier K. Continence. Part of the problem. Nurs Times. Mar 25–31. 1992;88(13):84-6. Case-Reports. [pmid: 1297104].
499 Bradley CS, Nygaard IE. Vaginal wall descensus and pelvic floor symptoms in older women. Obstet Gynecol. Oct. 2005;106(4):759-66. Not eligible level of evidence. [pmid: 16199633].
500 Bradley CS, Rovner ES. Urodynamically defined stress urinary incontinence and bladder outlet obstruction coexist in women. J Urol. Feb. 2004;171(2 Pt 1):757-60. discussion 60–1. Not eligible outcomes. [pmid: 14713804].
501 Bradley M, Ferris W, Barr O. Continence promotion in adults with learning disabilities. Nurs Times. Sep 277–Oct 3. 1995;91(39):38-9. Case Reports. [pmid: 7567555].
502 Bradshaw HD, Radley SC, Rosario DJ, et al. Towards a better understanding of involuntary detrusor activity. BJU Int. Apr. 2005;95(6):799-803. Not eligible outcomes. [pmid: 15794786].
503 Bradway C. Women's narratives of long-term urinary incontinence. Urol Nurs. Oct. 2005;25(5):337-44. Case-series. [pmid: 16294611].
504 Brady CM, Ahmed I, Drumm J, et al. A prospective evaluation of the efficiency of early postoperative bladder emptying after the Stamey procedure or pubovaginal sling for stress urinary incontinence. J Urol. May. 2001;165(5):1601-4. Case-series. [pmid: 11342926].
505 Brady CM, Apostolidis AN, Harper M, et al. Parallel changes in bladder suburothelial vanilloid receptor TRPV1 and pan-neuronal marker PGP9.5 immunoreactivity in patients with neurogenic detrusor overactivity after intravesical resiniferatoxin treatment. BJU Int. Apr. 2004;93(6):770-6. Not eligible exposure. [pmid: 15049988].
506 Brady CM, DasGupta R, Dalton C, et al. An open-label pilot study of cannabis-based extracts for bladder dysfunction in advanced multiple sclerosis. Mult Scler. Aug. 2004;10(4):425-33. Case-series. [pmid: 15327041].
507 Branagan G, Tromans A, Finnis D. Effect of stoma formation on bowel care and quality of life in patients with spinal cord injury. Spinal Cord. Dec. 2003;41(12):680-3. Not eligible outcomes. [pmid: 14639447].
508 Brandeis GH, Baumann MM, Hossain M, et al. The prevalence of potentially remediable urinary incontinence in frail older people: a study using the Minimum Data Set... presented in abstract form at the Annual Meeting of the American Geriatrics Society, Los Angeles, California, May 20, 1994. Journal of the American Geriatrics Society. Feb. 1997;45(2):179-84. Not eligible level of evidence. [pmid: 9033516].
509 Brandt FT, Albuquerque CD, Lorenzato FR, et al. Perineal assessment of urethrovesical junction mobility in young continent females. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(1):18-22. Not eligible target population. [pmid: 10738930].
510 Braslis KG, Bowsher WG, Joyce G, et al. Evolving experience with radical prostatectomy. Br J Urol. Sep. 1993;72(3):341-8. Not eligible exposure. [pmid: 8220994].
511 Braslis KG, Santa-Cruz C, Brickman AL, et al. Quality of life 12 months after radical prostatectomy. Br J Urol. Jan. 1995;75(1):48-53. Case-series. [pmid: 7850295].
512 Braslis KG, Stephens DA. Uretero-fallopian fistula: an unusual complication of open ureterolithotomy. J Urol. Dec. 1993;150(6):1900-2. Case Reports. [pmid: 8230531].
513 Braun J, Treutner KH, Schumpelick V. Stapled ileal pouch-anal anastomosis with resection of the anal transition zone. Int J Colorectal Dis. 1995;10(3):142-7. Case-series. [pmid: 7561431].
514 Braun PM, Boschert J, Bross S, et al. Tailored laminectomy: a new technique for neuromodulator implantation. J Urol. Nov. 1999;162(5):1607-9. Not eligible target population. [pmid: 10524878].
515 Braverman DL, Lachmann EA, Tunkel R, et al. Multiple sclerosis presenting as a spinal cord tumor. Arch Phys Med Rehabil. Nov. 1997;78(11):1274-6. Not eligible exposure. [pmid: 9365361].
516 Bravo Gutierrez A, Madoff RD, Lowry AC, et al. Long-term results of anterior sphincteroplasty. Dis Colon Rectum. May. 2004;47(5):727-31. discussion 31–2. Case-series. [pmid: 15037931].
517 Bremmer S, Mellgren A, Holmstrom B, et al. Peritoneocele: visualization with defecography and peritoneography performed simultaneously. Radiology. Feb. 1997;202(2):373-7. Not eligible outcomes. [pmid: 9015060].
518 Brendler CB, Walsh PC. The role of radical prostatectomy in the treatment of prostate cancer. CA Cancer J Clin. Jul–Aug. 1992;42(4):212-22. Review. [pmid: 1623431].
519 Bretagnol F, Rullier E, Laurent C, et al. Comparison of functional results and quality of life between intersphincteric resection and conventional coloanal anastomosis for low rectal cancer. Dis Colon Rectum. Jun. 2004;47(6):832-8. Case-series. [pmid: 15108027].
520 Bretagnol F, Troubat H, Laurent C, et al. Long-term functional results after sphincter-saving resection for rectal cancer. Gastroenterol Clin Biol. Feb. 2004;28(2):155-9. Case-series. [pmid: 15060460].
521 Brett TD. Patients' attitudes to prostate cancer. Aust Fam Physician. Jul. 1998;27(Suppl 2):S84-8. Not eligible outcomes. [pmid: 9679361].
522 Breza J, Alemayehu HM, Hornak M, et al. Advantages of converting incontinent to continent urinary diversion. Int Urol Nephrol. 1994;26(4):447-53. Case-series. [pmid: 8002219].
523 Breza J, Hornak M, Bardos A, et al. Transformation of the Bricker to a continent urinary reservoir to eliminate severe complications of uretero-ileostomy performed in eight patients among 200 Bricker. Ann Urol (Paris). 1995;29(4):227-31. Case-series. [pmid: 8554293].
524 Brieger G, Korda A. The effect of obesity on the outcome of successful surgery for genuine stress incontinence. Aust N Z J Obstet Gynaecol. Feb. 1992;32(1):71-2. Case-series. [pmid: 1586341].
525 Brieger GM, Yip SK, Fung YM, et al. Genital prolapse: a legacy of the West?. Aust N Z J Obstet Gynaecol. Feb. 1996;36(1):52-4. Not eligible target population. [pmid: 8775252].
526 Briel JW, de Boer LM, Hop WC, et al. Clinical outcome of anterior overlapping external anal sphincter repair with internal anal sphincter imbrication. Dis Colon Rectum. Feb. 1998;41(2):209-14. Case-series. [pmid: 9556246].
527 Briel JW, Schouten WR, Boerma MO. Long-term results of suture rectopexy in patients with fecal incontinence associated with incomplete rectal prolapse. Dis Colon Rectum. Oct. 1997;40(10):1228-32. Case-series. [pmid: 9336118].
528 Briel JW, Schouten WR, Vlot EA, et al. Clinical value of colonic irrigation in patients with continence disturbances. Dis Colon Rectum. Jul. 1997;40(7):802-5. Case-series. [pmid: 9221856].
529 Briel JW, Stoker J, Rociu E, et al. External anal sphincter atrophy on endoanal magnetic resonance imaging adversely affects continence after sphincteroplasty. Br J Surg. Oct. 1999;86(10):1322-7. Case-series. [pmid: 10540142].
530 Briel JW, Zimmerman DD, Stoker J, et al. Relationship between sphincter morphology on endoanal MRI and histopathological aspects of the external anal sphincter. Int J Colorectal Dis. Apr. 2000;15(2):87-90. Not eligible outcomes. [pmid: 10855549].
531 Bright T, Kapoor R, Voyvodich F, et al. The use of a balloon catheter to improve evaluation in anorectal manometry. Colorectal Dis. Jan. 2005;7(1):4-7. Not eligible exposure. [pmid: 15606577].
532 Brincat C, Kenton K, Pat Fitzgerald M, et al. Sexual activity predicts continued pessary use. Am J Obstet Gynecol. Jul. 2004;191(1):198-200. Not eligible outcomes. [pmid: 15295365].
533 Britnell SJ, Cole JV, Isherwood L, et al. Postural health in women: the role of physiotherapy. J Obstet Gynaecol Can. May. 2005;27(5):493-510. Practice Guideline. [pmid: 16100646].
534 Brittain K. Stroke and continence care. Nurs Times. Jul 26–Aug 1. 2001;97(30):57. Comment. [pmid: 11957960].
535 Brocklehurst J. Constipation and faecal incontinence. Nurs Elder. Feb. 1990;2(2):17-8. Comment.
536 Brocklehurst J, Dickinson E, Windsor J. Laxatives and faecal incontinence in long-term care. Nurs Stand. Sep 15–21. 1999;13(52):32-6. Not eligible outcomes.
537 Brodak PP, Juma S, Raz S. Levator hernia. J Urol. Sep. 1992;148(3):872-3. Case Reports. [pmid: 1512842].
538 Brodsky JT, Sloane BB, Khanna OP. Total pelvic exenteration with preservation of fecal continence. J Surg Oncol. Aug. 1993;53(4):261-4. Case Reports. [pmid: 8341059].
539 Broens P, Van Limbergen E, Penninckx F, et al. Clinical and manometric effects of combined external beam irradiation and brachytherapy for anal cancer. Int J Colorectal Dis. 1998;13(2):68-72. Case-series. [pmid: 9638490].
540 Brolmann HA, Vervest HA, Heineman MJ. Declining trend in major gynaecological surgery in The Netherlands during 1991-1998. Is there an impact on surgical skills and innovative ability?. Bjog. Jul. 2001;108(7):743-8. Not eligible outcomes. [pmid: 11467702].
541 Brookes E. Continence—independent means. Nurs Times 1997 Jul 23–29; 93(30):68–70, 2–3. Comment
542 Brooks MJ. Urinary incontinence: assessment, treatment, and reimbursement. Home Healthc Nurse. Jul–Aug. 1993;11(4):41-6. Case-Reports. [pmid: 8365908].
543 Brooks MJ. Assessment and nursing management of homebound clients with urinary incontinence. Home Healthc Nurse 1995 Sep–Oct; 13(5):11–6; quiz 7–9. Not eligible target population
544 Brooks V. Treat incontinence early. Nurs Stand. May 1–7. 2002;16(33):22. Comment. [pmid: 12035302].
545 Broome BA. Psychometric analysis of the Broome Pelvic Muscle Self-Efficacy Scale in African-American women with incontinence. Urol Nurs. Aug. 2001;21(4):289-97. Not eligible outcomes. [pmid: 11998458].
546 Broseta E, Osca JM, Morera J, et al. Urological manifestations of herpes zoster. Eur Urol. 1993;24(2):244-7. Not eligible exposure. [pmid: 8375446].
547 Brown AF, Mangione CM, Saliba D, et al. Guidelines for improving the care of the older person with diabetes mellitus. J Am Geriatr Soc. May. 2003;51(5 Suppl Guidelines):S265-80. Guideline. [pmid: 12694461].
548 Brown J, Thomas E, White H, et al. An incontinence helpline service. Nurs Stand. Jun 12–18. 1991;5(38):25-7. Comment. [pmid: 1907173].
549 Brown JS. Epidemiology and changing demographics of overactive bladder: a focus on the postmenopausal woman. Geriatrics. May. 2002;57(Suppl 1):6-12. Review. [pmid: 12040602].
550 Brown JS, McNaughton KS, Wyman JF, et al. Measurement characteristics of a voiding diary for use by men and women with overactive bladder. Urology. Apr. 2003;61(4):802-9. Not eligible outcomes. [pmid: 12670569].
551 Brown JS, Vittinghoff E, Kanaya AM, et al. Urinary tract infections in postmenopausal women: effect of hormone therapy and risk factors. Obstet Gynecol. Dec. 2001;98(6):1045-52. Not eligible outcomes. [pmid: 11755552].
552 Brown JS, Vittinghoff E, Wyman JF, et al. Urinary incontinence: does it increase risk for falls and fractures? Study of Osteoporotic Fractures Research Group. J Am Geriatr Soc. Jul. 2000;48(7):721-5. Not eligible outcomes. [pmid: 10894308].
553 Brown JS, Waetjen LE, Subak LL, et al. Pelvic organ prolapse surgery in the United States, 1997. Am J Obstet Gynecol. Apr. 2002;186(4):712-6. Not eligible outcomes. [pmid: 11967496].
554 Brown K, Hilton P. The incidence of detrusor instability before and after colposuspension: a study using conventional and ambulatory urodynamic monitoring. BJU Int. Dec. 1999;84(9):961-5. Not eligible outcomes. [pmid: 10571620].
555 Brown S. Winning treatment. Interview by Jennifer Taylor. Nurs Times. Nov 12–18. 2002;98(46):42-3. Interview. [pmid: 12478934].
556 Brown S, Lumley J. Physical health problems after childbirth and maternal depression at six to seven months postpartum. Bjog. Oct. 2000;107(10):1194-201. Not eligible level of evidence. [pmid: 11028568].
557 Brown SL, Govier FE. Cadaveric versus autologous fascia lata for the pubovaginal sling: surgical outcome and patient satisfaction. J Urol. Nov. 2000;164(5):1633-7. Case-series. [pmid: 11025722].
558 Brown WJ, Miller YD. Too wet to exercise? Leaking urine as a barrier to physical activity in women. J Sci Med Sport. Dec. 2001;4(4):373-8. Not eligible level of evidence. [pmid: 11905931].
559 Browning A. A new technique for the surgical management of urinary incontinence after obstetric fistula repair. Bjog. Apr. 2006;113(4):475-8. Comment. [pmid: 16489939].
560 Browning A. Risk factors for developing residual urinary incontinence after obstetric fistula repair. Bjog. Apr. 2006;113(4):482-5. Not eligible level of evidence. [pmid: 16489933].
561 Browning RH. What's wrong with this patient?. Rn. Jan. 2002;65(1):47-9. Case-series. [pmid: 15328856].
562 Brownlee RD, Clark AW, Sevick RJ, et al. Symptomatic hamartoma of the spinal cord associated with neurofibromatosis type 1. Case report. J Neurosurg. Jun. 1998;88(6):1099-103. Case report. [pmid: 9609307].
563 Brubaker L. Sacrocolpopexy and the anterior compartment: support and function. Am J Obstet Gynecol. Dec. 1995;173(6):1690-5. discussion 5–6. Case-series. [pmid: 8610746].
564 Brubaker L, Harris T, Gleason D, et al. The external urethral barrier for stress incontinence: a multicenter trial of safety and efficacy. Miniguard Investigators Group. Obstet Gynecol. Jun. 1999;93(6):932-7. Not eligible target population. [pmid: 10362157].
565 Brubaker L, Retzky S, Smith C, et al. Pelvic floor evaluation with dynamic fluoroscopy. Obstet Gynecol. Nov. 1993;82(5):863-8. Not eligible outcomes. [pmid: 8414340].
566 Bruce DG, Casey GP, Grange V, et al. Cognitive impairment, physical disability and depressive symptoms in older diabetic patients: the Fremantle Cognition in Diabetes Study. Diabetes Res Clin Pract. Jul. 2003;61(1):59-67. Not eligible level of evidence. [pmid: 12849924].
567 Bruce RG, El-Galley RE, Galloway NT. Paravaginal defect repair in the treatment of female stress urinary incontinence and cystocele. Urology. Oct. 1999;54(4):647-51. Case-series. [pmid: 10510922].
568 Bruce RG, el-Galley RE, Wells J, et al. Antegrade continence enema for the treatment of fecal incontinence in adults: use of gastric tube for catheterizable access to the descending colon. J Urol. Jun. 1999;161(6):1813-6. Case-series. [pmid: 10332442].
569 Brunenberg DE, Joore MA, Veraart CP, et al. Economic evaluation of duloxetine for the treatment of women with stress urinary incontinence: a Markov model comparing pharmacotherapy with pelvic floor muscle training. Clin Ther. Apr. 2006;28(4):604-18. Not eligible outcomes. [pmid: 16750472].
570 Bruner DW, Hanlon A, Mazzoni S, et al. Predictors of preferences and utilities in men treated with 3D-CRT for prostate cancer. Int J Radiat Oncol Biol Phys. Jan 1. 2004;58(1):34-42. Case-series. [pmid: 14697418].
571 Brusciano L, Ayabaca SM, Pescatori M, et al. Reinterventions after complicated or failed stapled hemorrhoidopexy. Dis Colon Rectum. Nov. 2004;47(11):1846-51. Case-series. [pmid: 15622576].
572 Bruyere F, Sun J, Cosson JP, et al. Incarceration of bowel through opening of a 5-mm port. J Endourol. Sep. 2004;18(7):675-6. Case Reports. [pmid: 15597661].
573 Bryant JE, Bueschen AJ, Cohn JH, et al. Transurethral prostatectomy: analysis and comparison of four clinical series. South Med J. Apr. 1990;83(4):386-9. Case Series. [pmid: 2181688].
574 Brylewski JE, Wiggs L. A questionnaire survey of sleep and night-time behaviour in a community-based sample of adults with intellectual disability. J Intellect Disabil Res. Apr. 1998;42(Pt 2):154-62. Not eligible level of evidence. [pmid: 9617699].
575 Buchanan RJ, Wang S, Huang C, et al. Analyses of nursing home residents with Parkinson's disease using the minimum data set. Parkinsonism Relat Disord. Jun. 2002;8(5):369-80. Not eligible outcomes. [pmid: 15177067].
576 Buchsbaum GM, Albushies DT, Schoenecker E, et al. Local anesthesia with sedation for vaginal reconstructive surgery. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):211-4. Case-series. [pmid: 16049625].
577 Buchsbaum GM, Duecy EE, Kerr LA, et al. Urinary incontinence in nulliparous women and their parous sisters. Obstet Gynecol. Dec. 2005;106(6):1253-8. Not eligible level of evidence. [pmid: 16319249].
578 Buchsbaum GM, Moll C, Duecy EE. True occult bladder perforation during placement of tension-free vaginal tape. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2004;15(6):432-3. Case report. [pmid: 15490119].
579 Buffa P, Torre M, Scarsi PL, et al. Caudal regression syndrome: an online multicentre survey. Urological long-term results. Eur J Pediatr Surg. Dec. 2002;12(Suppl 1):S26-8. Not eligible target population. [pmid: 12585250].
580 Buie WD, Lowry AC, Rothenberger DA, et al. Clinical rather than laboratory assessment predicts continence after anterior sphincteroplasty. Dis Colon Rectum. Sep. 2001;44(9):1255-60. Case-series. [pmid: 11584195].
581 Bukkapatnam R, Shah S, Raz S, et al. Anterior vaginal wall surgery in elderly patients: outcomes and assessment. Urology. Jun. 2005;65(6):1104-8. Case-series. [pmid: 15953501].
582 Bulent Tiras M, Sendag F, Dilek U, et al. Laparoscopic burch colposuspension: comparison of effectiveness of extraperitoneal and transperitoneal techniques. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2004;116(1):79-84. Case-series. [pmid: 15294373].
583 Bull E, Chilton CP, Gould CA, et al. Single-blind, randomised, parallel group study of the Bard Biocath catheter and a silicone elastomer coated catheter. Br J Urol. Oct. 1991;68(4):394-9. Not eligible outcomes. [pmid: 1933160].
584 Bullard KM, Madoff RD, Gemlo BT. Is ileoanal pouch function stable with time? Results of a prospective audit. Dis Colon Rectum. Mar. 2002;45(3):299-304. Case-series. [pmid: 12068184].
585 Bulmer PJ, James M, Ellis-Jones J, et al. A randomized trial comparing the effectiveness and preference of a touch-screen computer system with a leaflet for providing women with information on urinary symptoms suggestive of detrusor instability. BJU Int. Oct. 2001;88(6):532-5. Not eligible outcomes. [pmid: 11678745].
586 Bump RC. Racial comparisons and contrasts in urinary incontinence and pelvic organ prolapse. Obstet Gynecol. Mar. 1993;81(3):421-5. Not eligible target population. [pmid: 8437798].
587 Bump RC. The urethrodetrusor facilitative reflex in women: results of urethral perfusion studies. Am J Obstet Gynecol. Apr. 2000;182(4):794-802. discussion -4. Not eligible outcomes. [pmid: 10764455].
588 Bump RC, Coates KW, Cundiff GW, et al. Diagnosing intrinsic sphincteric deficiency: comparing urethral closure pressure, urethral axis, and Valsalva leak point pressures. Am J Obstet Gynecol. Aug. 1997;177(2):303-10. Not eligible outcomes. [pmid: 9290444].
589 Bump RC, Elser DM, Theofrastous JP, et al. Valsalva leak point pressures in women with genuine stress incontinence: reproducibility, effect of catheter caliber, and correlations with other measures of urethral resistance. Continence Program for Women Research Group. Am J Obstet Gynecol. Aug. 1995;173(2):551-7. Not eligible outcomes. [pmid: 7645634].
590 Bump RC, Hurt WG, Addison WA, et al. Reliability and correlation of measurements during and after bladder neck surgery. The Continence Program for Women Research Group. Br J Urol. Nov. 1998;82(5):628-33. Not eligible outcomes. [pmid: 9839575].
591 Bump RC, Hurt WG, Fantl JA, et al. Assessment of Kegel pelvic muscle exercise performance after brief verbal instruction. Am J Obstet Gynecol. Aug. 1991;165(2):322-7. discussion 7–9. Case-series. [pmid: 1872333].
592 Bump RC, McClish DK. Cigarette smoking and urinary incontinence in women. Am J Obstet Gynecol. Nov. 1992;167(5):1213-8. Not eligible level of evidence. [pmid: 1442969].
593 Bump RC, McClish DM. Cigarette smoking and pure genuine stress incontinence of urine: a comparison of risk factors and determinants between smokers and nonsmokers. Am J Obstet Gynecol. Feb. 1994;170(2):579-82. Not eligible target population. [pmid: 8116716].
594 Bump RC, Norton PA, Zinner NR, et al. Mixed urinary incontinence symptoms: urodynamic findings, incontinence severity, and treatment response. Obstet Gynecol. Jul. 2003;102(1):76-83. Not eligible exposure. [pmid: 12850610].
595 Bump RC, Sugerman HJ, Fantl JA, et al. Obesity and lower urinary tract function in women: effect of surgically induced weight loss. Am J Obstet Gynecol. Aug. 1992;167(2):392-7. discussion 7–9. Case-series. [pmid: 1497041].
596 Buntzen S, Rasmussen OO, Ryhammer AM, et al. Sacral nerve stimulation for treatment of fecal incontinence in a patient with muscular dystrophy: report of a case. Dis Colon Rectum. Aug. 2004;47(8):1409-11. Case-reports. [pmid: 15175928].
597 Bunyavejchevin S. Risk factors of female urinary incontinence and overactive bladder in Thai postmenopausal women. J Med Assoc Thai. Sep. 2005;88(Suppl 4):S119-23. Not eligible level of evidence.
598 Bunyavejchevin S. Can pre-operative urodynamic study predict the successful outcome of tension free vaginal tape (TVT) operation in Thai women with stress urinary incontinence?. J Med Assoc Thai. Nov. 2005;88(11):1493-6. Case-series. [pmid: 16471091].
599 Bunyavejchevin S. The impact of overactive bladder, stress and mixed urinary incontinence on quality of life in Thai postmenopausal women. J Med Assoc Thai. Mar. 2006;89(3):294-8. Not eligible outcomes. [pmid: 16696411].
600 Bunyavejchevin S, Santingamkun A, Wisawasukmongchol W. The three years results of tension free vaginal tape (TVT) for the treatment of stress urinary incontinence in Thai women. J Med Assoc Thai. Jan. 2005;88(1):5-8. Case-series. [pmid: 15960209].
601 Bunyavejchevin S, Veeranarapanich S. Quality of life assessment in Thai postmenopausal women with an overactive bladder. J Med Assoc Thai. Aug. 2005;88(8):1023-7. Not eligible outcomes. [pmid: 16404827].
602 Bunyavejchevin S, Wisawasukmongchol W. Five years follow up of laparoscopic burch colposuspension for stress urinary incontinence in Thai women. J Med Assoc Thai. Sep. 2005;88(9):1182-6. Case-series. [pmid: 16536102].
603 Burgio KL. Behavioral training for stress and urge incontinence in the community. Gerontology. 1990;36(Suppl 2):27-34. No associative hypothesis tested. [pmid: 2227473].
604 Burgio KL, Engel BT. Biofeedback-assisted behavioral training for elderly men and women. J Am Geriatr Soc. Mar. 1990;38(3):338-40. Comment. [pmid: 2313011].
605 Burgio KL, Goode PS, Locher JL, et al. Predictors of outcome in the behavioral treatment of urinary incontinence in women. Obstet Gynecol. Nov. 2003;102(5 Pt 1):940-7. Review. [pmid: 14672467].
606 Burgio KL, Goode PS, Richter HE, et al. Global ratings of patient satisfaction and perceptions of improvement with treatment for urinary incontinence: validation of three global patient ratings. Neurourol Urodyn. 2006;25(5):411-7. Review. [pmid: 16652380].
607 Burgio KL, Ives DG, Locher JL, et al. Treatment seeking for urinary incontinence in older adults. J Am Geriatr Soc. Feb. 1994;42(2):208-12. Not eligible outcomes. [pmid: 8126338].
608 Burgio KL, Locher JL, Goode PS. Combined behavioral and drug therapy for urge incontinence in older women. J Am Geriatr Soc. Apr. 2000;48(4):370-4. Not eligible exposure. [pmid: 10798461].
609 Burgio KL, Locher JL, Goode PS, et al. Behavioral vs drug treatment for urge urinary incontinence in older women: a randomized controlled trial. JAMA. Dec 16. 1998;280(23):1995-2000. Secondary data report. [pmid: 9863850].
610 Burgio KL, Locher JL, Roth DL, et al. Psychological improvements associated with behavioral and drug treatment of urge incontinence in older women. J Gerontol B Psychol Sci Soc Sci. Jan. 2001;56(1):P46-51. Not eligible outcomes. [pmid: 11192337].
611 Burgio LD, Engel BT, Hawkins A, et al. A staff management system for maintaining improvements in continence with elderly nursing home residents. J Appl Behav Anal. Spring. 1990;23(1):111-8. Case-series. [pmid: 2335482]. [pmcid: 1286215].
612 Burke ER, Welvaart K. Complications of stapled anastomoses in anterior resection for rectal carcinoma: colorectal anastomosis versus coloanal anastomosis. J Surg Oncol. Nov. 1990;45(3):180-3. Case-series. [pmid: 2232808].
613 Burnett SJ, Speakman CT, Kamm MA, et al. Confirmation of endosonographic detection of external anal sphincter defects by simultaneous electromyographic mapping. Br J Surg. Apr. 1991;78(4):448-50. No associative hypothesis tested. [pmid: 2032104].
614 Burnett SJ, Spence-Jones C, Speakman CT, et al. Unsuspected sphincter damage following childbirth revealed by anal endosonography. Br J Radiol. Mar. 1991;64(759):225-7. Not eligible outcomes. [pmid: 2021796].
615 Burns A, Jacoby R, Levy R. Psychiatric phenomena in Alzheimer's disease. IV: Disorders of behaviour. Br J Psychiatry. Jul. 1990;157:86-94. Not eligible exposure. [pmid: 2397368].
616 Buron C, Le Vu B, Cosset JM, et al. Brachytherapy versus prostatectomy in localized prostate cancer: results of a French multicenter prospective medico-economic study. Int J Radiat Oncol Biol Phys. Mar 1. 2007;67(3):812-22. Case-series. [pmid: 17293235].
617 Burt J, Caelli K, Moore K, et al. Radical prostatectomy: men's experiences and postoperative needs. J Clin Nurs. Aug. 2005;14(7):883-90. Not eligible outcomes. [pmid: 16000103].
618 Busacchi P, De Giorgio R, Santini D, et al. A histological and immunohistochemical study of neuropeptide containing somatic nerves in the levator ani muscle of women with genitourinary prolapse. Acta Obstet Gynecol Scand. Jan. 1999;78(1):2-5. Not eligible outcomes. [pmid: 9926883].
619 Busacchi P, Perri T, Paradisi R, et al. Abnormalities of somatic peptide-containing nerves supplying the pelvic floor of women with genitourinary prolapse and stress urinary incontinence. Urology. Mar. 2004;63(3):591-5. Not eligible outcomes. [pmid: 15028474].
620 Bushman W, Steers WD, Meythaler JM. Voiding dysfunction in patients with spastic paraplegia: urodynamic evaluation and response to continuous intrathecal baclofen. Neurourol Urodyn. 1993;12(2):163-70. Case-reports. [pmid: 7920673].
621 But I. Vaginal wall erosion after transobturator tape procedure. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):506-8. Case-reports. [pmid: 15645145].
622 But I, Bratus D, Faganelj M. Prolene tape in the bladder wall after TVT procedure—intramural tape placement or secondary tape migration. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):75-6. Case Reports. [pmid: 15309281].
623 Butler L, Downe-Wamboldt B, Marsh S, et al. Behind the scenes: partners' perceptions of quality of life post radical prostatectomy. Urol Nurs. Aug. 2000;20(4):254-8. Not eligible target population. [pmid: 11998088].
624 Butler L, Downe-Wamboldt B, Marsh S, et al. Quality of life post radical prostatectomy: a male perspective. Urol Nurs. Aug. 2001;21(4):283-8. Case-series. [pmid: 11998457].
625 Butler RN, August P, Ferdinand KC, et al. Hypertension: how comorbid disease influences the choice of therapy. Part 4 of a roundtable discussion. Geriatrics 1999 Aug; 54(8):34, 9–44. No associative hypothesis tested
626 Butler RN, Maby JI, Montella JM, et al. Urinary incontinence: primary care therapies for the older woman. Geriatrics 1999 Nov; 54(11):31–4, 9–40, 3–4. Comment
627 Butler RN, Maby JI, Montella JM, et al. Urinary incontinence: keys to diagnosis of the older woman.1. Geriatrics 1999 Oct; 54(10):22–6, 9–30. Comment
628 Butler RN, Maby JI, Montella JM, et al. Urinary incontinence: when to refer for procedural therapies. Geriatrics 1999 Dec; 54(12):49–54, 6. Case-series
629 Buttafuoco A, Keighley MR. Cost of pelvic floor repair for faecal incontinence. Dig Surg. 2000;17(6):623-6. Not eligible outcomes. [pmid: 11155009].
630 Butteriss D, Soh C. A case of spinal cord compression of unknown cause. Br J Radiol. Sep. 2006;79(945):775-7. Case report. [pmid: 16940377].
631 Butturini E. Pants are back in style!. N Z Health Hospital. May–Jun. 1990;42(3):14-9. Comment. [pmid: 10105966].
632 Butturini E. Pants for incontinence patients. N Z Nurs J. Oct. 1990;83(9):26. Case-series. [pmid: 2122337].
633 Byck DB, Varner RE, Clough C. Urinary complaints after modified Burch urethropexy: an analysis. Am J Obstet Gynecol. Dec. 1994;171(6):1460-2. discussion 2–4. Case-series. [pmid: 7802054].
634 Byers PH, Ryan PA, Regan MB, et al. Effects of incontinence care cleansing regimens on skin integrity. J Wound Ostomy Continence Nurs. Jul. 1995;22(4):187-92. Not eligible outcomes. [pmid: 7627294].
635 Byrne CM, Solomon MJ, Young JM, et al. Biofeedback for fecal incontinence: short-term outcomes of 513 consecutive patients and predictors of successful treatment. Dis Colon Rectum. Apr. 2007;50(4):417-27. Case-series. [pmid: 17476558].
636 Cain MP, Casale AJ, King SJ, et al. Appendicovesicostomy and newer alternatives for the Mitrofanoff procedure: results in the last 100 patients at Riley Children's Hospital. J Urol. Nov. 1999;162(5):1749-52. Not eligible target population. [pmid: 10524929].
637 Cam C, Sakalli M, Ay P, et al. Validation of the short forms of the incontinence impact questionnaire (IIQ-7) and the urogenital distress inventory (UDI-6) in a Turkish population. Neurourol Urodyn. 2007;26(1):129-33. Not eligible exposure. [pmid: 17083117].
638 Cammu H, Van Nylen M, Blockeel C, et al. Who will benefit from pelvic floor muscle training for stress urinary incontinence?. Am J Obstet Gynecol. Oct. 2004;191(4):1152-7. Not eligible target population. [pmid: 15507935].
639 Cammu H, Van Nylen M, Derde MP, et al. Pelvic physiotherapy in genuine stress incontinence. Urology. Oct. 1991;38(4):332-7. No associative hypothesis tested. [pmid: 1755141].
640 Campbell DM, Behan M, Donnelly VS, et al. Endosonographic assessment of postpartum anal sphincter injury using a 120 degree sector scanner. Clin Radiol. Aug. 1996;51(8):559-61. Not eligible outcomes. [pmid: 8761392].
641 Canning DA. Modification of meatal advancement and glanuloplasty for correction of distal hypospadias. J Urol. Jun. 2005;173(6):2144-5. Comment.
642 Capar M. A new retropubic suspension operation technique for transvaginal Burch operation, using newly developed equipment. Acta Obstet Gynecol Scand. Oct. 2004;83(10):898-903. Case-series. [pmid: 15453882].
643 Capitanucci ML, Iacobelli BD, Silveri M, et al. Long-term urological follow-up of occult spinal dysraphism in children. Eur J Pediatr Surg. Dec. 1996;6(Suppl 1):25-6. Not eligible target population.
644 Caputo RM, Benson JT, McClellan E. Intravaginal maximal electrical stimulation in the treatment of urinary incontinence. J Reprod Med. Sep. 1993;38(9):667-71. Case-series. [pmid: 8254586].
645 Caquant F, Collinet P, Deruelle P, et al. Perineal cellulitis following trans-obturator sub-urethral tape Uratape. Eur Urol. Jan. 2005;47(1):108-10. Case Reports. [pmid: 15582258].
646 Caraballo R, Bologna RA, Lukban J, et al. Sacral nerve stimulation as a treatment for urge incontinence and associated pelvic floor disorders at a pelvic floor center: a follow-up study. Urology. Jun. 2001;57(6 Suppl 1):121. Case-series.
647 Carbone JM, Kavaler E, Hu JC, et al. Pubovaginal sling using cadaveric fascia and bone anchors: disappointing early results. J Urol. May. 2001;165(5):1605-11. Case-series. [pmid: 11342927].
648 Cardozo L. Role of estrogens in the treatment of female urinary incontinence. J Am Geriatr Soc. Mar. 1990;38(3):326-8. Review. [pmid: 2179376].
649 Cardozo L, Brindley GS. Endoscopically guided bladder neck suspension for continence in paraplegic women with implant driven micturition. Paraplegia. May. 1992;30(5):336-8. Case-Reports. [pmid: 1598173].
650 Cardozo L, Dixon A. Increased warning time with darifenacin: a new concept in the management of urinary urgency. J Urol. Apr. 2005;173(4):1214-8. Not eligible exposure. [pmid: 15758755].
651 Cardozo L, Drutz HP, Baygani SK, et al. Pharmacological treatment of women awaiting surgery for stress urinary incontinence. Obstet Gynecol. Sep. 2004;104(3):511-9. Not eligible exposure. [pmid: 15339761].
652 Cardozo L, Hextall A, Bailey J, et al. Colposuspension after previous failed incontinence surgery: a prospective observational study. Br J Obstet Gynaecol. Apr. 1999;106(4):340-4. Case-series. [pmid: 10426240].
653 Cardozo L, Lisec M, Millard R, et al. Randomized, double-blind placebo controlled trial of the once daily antimuscarinic agent solifenacin succinate in patients with overactive bladder. J Urol. Nov. 2004;172(5 Pt 1):1919-24. Not eligible exposure. [pmid: 15540755].
654 Carey JM, Leach GE. Transvaginal surgery in the octogenarian using cadaveric fascia for pelvic prolapse and stress incontinence: minimal one-year results compared to younger patients. Urology. Apr. 2004;63(4):665-70. Case-series. [pmid: 15072875].
655 Carey MP, De Jong S, Friedhuber A, et al. A prospective evaluation of the pathogenesis of detrusor instability in women, using electron microscopy and immunohistochemistry. BJU Int. Dec. 2000;86(9):970-6. Not eligible exposure. [pmid: 11119088].
656 Carey MP, Dwyer PL. Position and mobility of the urethrovesical junction in continent and in stress incontinent women before and after successful surgery. Aust N Z J Obstet Gynaecol. Aug. 1991;31(3):279-84. Case-series. [pmid: 1804096].
657 Carey MP, Goh JT, Fynes MM, et al. Stress urinary incontinence after delayed primary closure of genitourinary fistula: a technique for surgical management. Am J Obstet Gynecol. May. 2002;186(5):948-53. Case-series. [pmid: 12015520].
658 Carini M, Serni S, Lapini A, et al. Second stage reconfiguration of Camey I ileal bladder improves its urodynamic and clinical characteristics. Urology. Sep. 1994;44(3):425-8. Case-series. [pmid: 8073559].
659 Carley ME, Schaffer J. Urinary incontinence and pelvic organ prolapse in women with Marfan or Ehlers Danlos syndrome. Am J Obstet Gynecol. May. 2000;182(5):1021-3. Case-series. [pmid: 10819815].
660 Carlisle D. Silent suffering. Nurs Times 1998 Apr 15–21; 94(15):63–4, 7. Comment
661 Carls C. The prevalence of stress urinary incontinence in high school and college-age female athletes in the midwest: implications for education and prevention. Urol Nurs 2007 Feb; 27(1):21–4, 39. Not eligible level of evidence
662 Carlsson S, Nilsson A, Wiklund PN. Postoperative urinary continence after robot-assisted laparoscopic radical prostatectomy. Scand J Urol Nephrol. 2006;40(2):103-7. Case-series. [pmid: 16608806].
663 Carmona JA, Ortiz H, Perez-Cabanas I. Alterations in anorectal function after anterior resection for cancer of the rectum. Int J Colorectal Dis. May. 1991;6(2):108-10. Case-series. [pmid: 1875118].
664 Caro FG, Glickman LL, Ingegneri D, et al. The impact of the closing of three Massachusetts public chronic disease hospitals: a multidimensional perspective. J Community Health. Jun. 1997;22(3):155-74. Not eligible exposure. [pmid: 9178116].
665 Carpelan-Holmstrom M, Kruuna O, Scheinin T. Laparoscopic rectal prolapse surgery combined with short hospital stay is safe in elderly and debilitated patients. Surg Endosc. Sep. 2006;20(9):1353-9. Case-series. [pmid: 16703440].
666 Carr LK, Herschorn S. Periurethral collagen injection and pregnancy. J Urol. Mar. 1996;155(3):1037. Case-reports. [pmid: 8583557].
667 Carr M. Continence promotion and management. Nurs BC. Apr. 2004;36(2):16-8. Comment. [pmid: 15176137].
668 Carranza-Lira S, Murillo-Uribe A, Martinez-Trejo N, et al. Changes in symptoms, blood pressure, glucose, hormones, and lipid levels according to weight and body fat distribution in climacteric women. Int J Fertil Womens Med. Nov–Dec. 1998;43(6):306-11. Question 2. [pmid: 9920540].
669 Carriero A, Dal Borgo P, Pucciani F. Stapled mucosal prolapsectomy for haemorrhoidal prolapse with Lone Star Retractor System. Tech Coloproctol. Apr. 2001;5(1):41-6. Case-series. [pmid: 11793260].
670 Carrion R, Arap S, Corcione G, et al. A multi-institutional study of orthotopic neobladders: functional results in men and women. BJU Int. Apr. 2004;93(6):803-6. Not eligible target population. [pmid: 15049993].
671 Carta G, Cerrone L, Iovenitti P. Tension-free vaginal tape procedure for treatment of USI: subjective and objective efficacy evaluation. Clin Exp Obstet Gynecol. 2002;29(4):247-50. Case-series. [pmid: 12635739].
672 Carter D, Green D. Health promotion. Applying COPC to incontinence. Nurs Times. Aug 31–Sep 6. 1994;90(35):44-5. Not associative hypothesis tested.
673 Cartier C. From home to hospital and back again: economic restructuring, end of life, and the gendered problems of place-switching health services. Soc Sci Med. Jun. 2003;56(11):2289-301. Review. [pmid: 12719182].
674 Caruana BJ, Wald A, Hinds JP, et al. Anorectal sensory and motor function in neurogenic fecal incontinence. Comparison between multiple sclerosis and diabetes mellitus. Gastroenterology. Feb. 1991;100(2):465-70. Not eligible outcomes. [pmid: 1985043].
675 Casal E, San Ildefonso A, Carracedo R, et al. Artificial bowel sphincter in severe anal incontinence. Colorectal Dis. May. 2004;6(3):180-4. Case-series. [pmid: 15109383].
676 Casillas S, Hull TL, Zutshi M, et al. Incontinence after a lateral internal sphincterotomy: are we underestimating it?. Dis Colon Rectum. Jun. 2005;48(6):1193-9. Case-series. [pmid: 15906136].
677 Casper FW, Linn JF, Black P. Obstetrical management following incontinence surgery. J Obstet Gynaecol Res. Feb. 1999;25(1):51-3. Case-series. [pmid: 10067014].
678 Cassidy TP, Farquhar DL. The characteristics of respite patients. Health Bull (Edinb). Jan. 1995;53(1):13-9. Case-series. [pmid: 7868343].
679 Castellan M, Gosalbez R, Labbie A, et al. Bladder neck sling for treatment of neurogenic incontinence in children with augmentation cystoplasty: long-term followup. J Urol. Jun. 2005;173(6):2128-31. discussion 31. Not eligible target population. [pmid: 15879865].
680 Castera R, Podesta ML, Ruarte A, et al. 10-Year experience with artificial urinary sphincter in children and adolescents. J Urol. Jun. 2001;165(6 Pt 2):2373-6. Not eligible target population. [pmid: 11371980].
681 Castillo OA, Bodden E, Olivares RA, et al. Intestinal perforation: an infrequent complication during insertion of tension-free vaginal tape. J Urol. Oct. 2004;172(4 Pt 1):1364. Case-reports. [pmid: 15371844].
682 Castillo OA, Bodden EM, Vitagliano GJ, et al. Anterior transanal, transsphincteric sagittal approach for fistula repair secondary to laparoscopic radical prostatectomy: a simple and effective technique. Urology. Jul. 2006;68(1):198-201. Case-series. [pmid: 16806424].
683 Castina S, Boyington A, Dougherty M. Urinary incontinence. Am J Nurs. Aug. 2002;102(8):85-7. Comment. [pmid: 12394044].
684 Catalona WJ, Bigg SW. Nerve-sparing radical prostatectomy: evaluation of results after 250 patients. J Urol. Mar. 1990;143(3):538-43. discussion 44. Case Series. [pmid: 2304166].
685 Cavallaro A, Fellner F, Matzel KE, et al. Low-field magnetic resonance imaging of the pelvis in patients with anal dynamic graciloplasty: initial experience. Magma. Dec. 1998;7(3):179-83. Not eligible outcomes. [pmid: 10050944].
686 Cavanaugh M, Hyman N, Osler T. Fecal incontinence severity index after fistulotomy: a predictor of quality of life. Dis Colon Rectum. Mar. 2002;45(3):349-53. Not eligible outcomes. [pmid: 12068193].
687 Cavina E. Total anorectal reconstruction after abdominoperineal resection. Int J Surg Investig. 1999;1(3):262-3. Case-reports.
688 Cavina E, Seccia M, Chiarugi M, et al. Laparoscopically assisted abdominoperineal resection and simultaneous total anorectal reconstruction with electrostimulated static-dynamic graciloplasty. Surg Endosc. Dec. 1997;11(12):1209-12. Case Reports. [pmid: 9373296].
689 Cazemier M, Terra MP, Stoker J, et al. Atrophy and defects detection of the external anal sphincter: comparison between three-dimensional anal endosonography and endoanal magnetic resonance imaging. Dis Colon Rectum. Jan. 2006;49(1):20-7. Not eligible outcomes. [pmid: 16328609].
690 Cespedes RD. Anterior approach bilateral sacrospinous ligament fixation for vaginal vault prolapse. Urology. Dec 4. 2000;56(6 Suppl 1):70-5. Case-series. [pmid: 11114566].
691 Cespedes RD, Cross CA, McGuire EJ. Modified Ingelman-Sundberg bladder denervation procedure for intractable urge incontinence. J Urol. Nov. 1996;156(5):1744-7. Case-series. [pmid: 8863585].
692 Cespedes RD, Cross CA, McGuire EJ. Pubovaginal fascial slings. Tech Urol. Winter. 1997;3(4):195-201. Comment. [pmid: 9531102].
693 Cetinel B, Demirkesen O, Kural AR, et al. Polypropylene mesh tape for male sphincteric incontinence. Scand J Urol Nephrol. 2004;38(5):396-400. Case-series. [pmid: 15764251].
694 Cetinel B, Demirkesen O, Onal B, et al. Are there any factors predicting the cure and complication rates of tension-free vaginal tape?. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):188-93. Case-series. [pmid: 15167999].
695 Cetinel B, Demirkesen O, Talat Z, et al. Application of continent retubularized ileal stoma (Monti procedure) to an ileocecal pouch. Urology. Feb. 2000;55(2):286. Case-reports.
696 Ceulemans R, Creve U, Van Hee R, et al. Benefit of emergency haemorrhoidectomy: a comparison with results after elective operations. Eur J Surg. Oct. 2000;166(10):808-12. discussion 13. Not eligible outcomes. [pmid: 11071169].
697 Chadburn S, Haggar V, Gooch S. Developing a continence care programme. Prof Nurse. Oct. 1998;14(1):31-3. Case Reports. [pmid: 9866615].
698 Chaikin DC, Blaivas JG, Rosenthal JE, et al. Results of pubovaginal sling for stress incontinence: a prospective comparison of 4 instruments for outcome analysis. J Urol. Nov. 1999;162(5):1670-3. Not eligible outcomes. [pmid: 10524894].
699 Chaikin DC, Groutz A, Blaivas JG. Predicting the need for anti-incontinence surgery in continent women undergoing repair of severe urogenital prolapse. J Urol. Feb. 2000;163(2):531-4. Case-series. [pmid: 10647672].
700 Chait PG, Shandling B, Richards HM, et al. Fecal incontinence in children: treatment with percutaneous cecostomy tube placement—a prospective study. Radiology. Jun. 1997;203(3):621-4. Not eligible target population. [pmid: 9169678].
701 Chait PG, Shlomovitz E, Connolly BL, et al. Percutaneous cecostomy: updates in technique and patient care. Radiology. Apr. 2003;227(1):246-50. Not eligible target population. [pmid: 12601198].
702 Chaliha C, Bland JM, Monga A, et al. Pregnancy and delivery: a urodynamic viewpoint. Bjog. Nov. 2000;107(11):1354-9. Not eligible level of evidence. [pmid: 11117761].
703 Chaliha C, Digesu A, Hutchings A, et al. Caesarean section is protective against stress urinary incontinence: an analysis of women with multiple deliveries. Bjog. Jul. 2004;111(7):754-5. Not eligible level of evidence. [pmid: 15198768].
704 Chaliha C, Khullar V, Stanton SL, et al. Urinary symptoms in pregnancy: are they useful for diagnosis?. Bjog. Oct. 2002;109(10):1181-3. Not eligible outcomes. [pmid: 12387475].
705 Chaliha C, Stanton SL. The ethnic cultural and social aspects of incontinence—a pilot study. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):166-70. Case-series. [pmid: 10430009].
706 Challacombe B, Kelleher C, Sami T, et al. Laparoscopic nephroureterectomy for adult incontinence caused by functioning ectopic pelvic kidney draining into vagina. J Endourol. Jun. 2004;18(5):447-8. Case Reports. [pmid: 15253815].
707 Chambers K, et al. Continence. Regained dignity. Nurs Times. Nov 24–30. 1993;89(47):65-6. Case Reports. [pmid: 8265391].
708 Chan CL, Facer P, Davis JB, et al. Sensory fibres expressing capsaicin receptor TRPV1 in patients with rectal hypersensitivity and faecal urgency. Lancet. Feb 1. 2003;361(9355):385-91. Not eligible outcomes. [pmid: 12573376].
709 Chan CL, Lunniss PJ, Wang D, et al. Rectal sensorimotor dysfunction in patients with urge faecal incontinence: evidence from prolonged manometric studies. Gut. Sep. 2005;54(9):1263-72. Not eligible outcomes. [pmid: 15914573]. [pmcid: 1774666].
710 Chan KM, Lim PH, Chee YC, et al. Urinary symptoms and urodynamic diagnosis of patients in one geriatric department. Ann Acad Med Singapore. Nov. 1992;21(6):813-7. Case-series. [pmid: 1295423].
711 Chan LW, Pang MW, Yip SK. Arcus tendineus levator ani tear causing pelvic hematoma after tension-free vaginal tape insertion. Gynecol Obstet Invest. 2002;54(2):118. Case Reports. [pmid: 12566745].
712 Chan LW, Tse VW. Unrecognized bladder perforation while placing a suburethral synthetic sling: a minimally invasive technique for removing an intravesical sling segment. BJU Int. Jan. 2005;95(1):187-8. Case Reports. [pmid: 15638921].
713 Chan MK, Tjandra JJ. Injectable silicone biomaterial (PTQ) to treat fecal incontinence after hemorrhoidectomy. Dis Colon Rectum. Apr. 2006;49(4):433-9. Case-series. [pmid: 16482420].
714 Chan PT, Fournier C, Corcos J. Short-term complications of pubovaginal sling procedure for genuine stress incontinence in women. Urology. Feb. 2000;55(2):207-11. Case-series. [pmid: 10688080].
715 Chance R. A problem we need not take for granted. Prof Nurse. Apr. 1994;9(7):498-500. 2 passim. Comment. [pmid: 8177904].
716 Chancellor MB, Gajewski J, Ackman CF, et al. Long-term followup of the North American multicenter UroLume trial for the treatment of external detrusor-sphincter dyssynergia. J Urol. May. 1999;161(5):1545-50. Not eligible target population. [pmid: 10210393].
717 Chancellor MB, Hong RD, Rivas DA, et al. Gracilis urethromyoplasty—an autologous urinary sphincter for neurologically impaired patients with stress incontinence. Spinal Cord. Aug. 1997;35(8):546-9. Case-reports. [pmid: 9267922].
718 Chancellor MB, Rivas DA, Abdill CK, et al. Management of sphincter dyssynergia using the sphincter stent prosthesis in chronically catheterized SCI men. J Spinal Cord Med. Apr. 1995;18(2):88-94. Not eligible target population. [pmid: 7640978].
719 Chancellor MB, Rivas DA, Watanabe T, et al. Reversible clinical outcome after sphincter stent removal. J Urol. Jun. 1996;155(6):1992-4. Not eligible target population. [pmid: 8618306].
720 Chancellor MB, Strup S, Rivas DA, et al. Rectus urethromyoplasty of radical prostatectomy anastomosis decreases postoperative incontinence and anastomotic stricture; technique and preliminary results. J Urol. Jan. 1997;157(1):371-5. Not eligible target population. [pmid: 8976300].
721 Chancellor MB, Watanabe T, Rivas DA, et al. Gracilis urethral myoplasty: preliminary experience using an autologous urinary sphincter for post-prostatectomy incontinence. J Urol. Oct. 1997;158(4):1372-5. Case Reports. [pmid: 9302123].
722 Chander J, Gupta U, Mehra R, et al. Safety and efficacy of transurethral resection of the prostate under sedoanalgesia. BJU Int. Aug. 2000;86(3):220-2. Not eligible outcomes. [pmid: 10930918].
723 Chang HC, Chang SC, Kuo HC, et al. Transrectal sonographic cystourethrography: studies in stress urinary incontinence. Urology. Dec. 1990;36(6):488-92. Case-series. [pmid: 2247913].
724 Chang PL, Tsai LH, Huang ST, et al. The early effect of pelvic floor muscle exercise after transurethral prostatectomy. J Urol. Aug. 1998;160(2):402-5. Case-series. [pmid: 9679887].
725 Chang SC, Lin JK. Change in anal continence after surgery for intersphincteral anal fistula: a functional and manometric study. Int J Colorectal Dis. Mar. 2003;18(2):111-5. Case-series. [pmid: 12548411].
726 Chao R, Mayo ME. Incontinence after radical prostatectomy: detrusor or sphincter causes. J Urol. Jul. 1995;154(1):16-8. Case-series. [pmid: 7776413].
727 Chapelle T, Reher S, Denis B. Surgical extraction of a bladder stone due to a foreign body. Acta Urol Belg. 1992;60(1):85-7. Case-reports. [pmid: 1414723].
728 Chapman SM, Wemyss-Holden GD, Clarke NW. Urinary incontinence following urethral Wallstent insertion. Br J Urol. May. 1994;73(5):586. Case Reports. [pmid: 8012786].
729 Chapple CR, Abrams P. Comparison of darifenacin and oxybutynin in patients with overactive bladder: assessment of ambulatory urodynamics and impact on salivary flow. Eur Urol. Jul. 2005;48(1):102-9. Not eligible exposure. [pmid: 15936869].
730 Chapple CR, Haab F, Cervigni M, et al. An open, multicentre study of NASHA/Dx Gel (Zuidex) for the treatment of stress urinary incontinence. Eur Urol. Sep. 2005;48(3):488-94. Not eligible target population. [pmid: 15967568].
731 Chapple CR, Martinez-Garcia R, Selvaggi L, et al. A comparison of the efficacy and tolerability of solifenacin succinate and extended release tolterodine at treating overactive bladder syndrome: results of the STAR trial. Eur Urol. Sep. 2005;48(3):464-70. Not eligible exposure. [pmid: 15990220].
732 Chapple CR, Patroneva A, Raines SR. Effect of an ATP-sensitive potassium channel opener in subjects with overactive bladder: a randomized, double-blind, placebo-controlled study (ZD0947IL/0004). Eur Urol. May. 2006;49(5):879-86. Not eligible exposure. [pmid: 16517051].
733 Chapron C, Dubuisson JB, Ansquer Y, et al. Hysterectomy with adnexectomy. Can operative laparoscopy offer advantages?. J Reprod Med. Apr. 1997;42(4):201-6. Case-series. [pmid: 9131492].
734 Chartier-Kastler EJ, Mongiat-Artus P, Bitker MO, et al. Long-term results of augmentation cystoplasty in spinal cord injury patients. Spinal Cord. Aug. 2000;38(8):490-4. Case-series. [pmid: 10962609].
735 Chartier-Kastler EJ, Mozer P, Denys P, et al. Neurogenic bladder management and cutaneous non-continent ileal conduit. Spinal Cord. Sep. 2002;40(9):443-8. Case-series. [pmid: 12185605].
736 Chartier-Kastler EJ, Ruud Bosch JL, Perrigot M, et al. Long-term results of sacral nerve stimulation (S3) for the treatment of neurogenic refractory urge incontinence related to detrusor hyperreflexia. J Urol. Nov. 2000;164(5):1476-80. Not eligible target population. [pmid: 11025686].
737 Chartrand-Lefebvre C, Heppell J, Davignon I, et al. Dietary habits after ileal pouch-anal anastomosis. Can J Surg. Apr. 1990;33(2):101-5. Case-series. [pmid: 2268807].
738 Chatterjee US, Mandal MK, Basu S, et al. Comparative study of dartos fascia and tunica vaginalis pedicle wrap for the tubularized incised plate in primary hypospadias repair. BJU Int. Nov. 2004;94(7):1102-4. Not eligible target population. [pmid: 15541136].
739 Chatwin NA, Ribordy M, Givel JC. Clinical outcomes and quality of life after low anterior resection for rectal cancer. Eur J Surg. 2002;168(5):297-301. Case-series. [pmid: 12375612].
740 Chatzopoulos C, Lorge FJ, Opsomer RJ, et al. Transurethral ultrasound-guided laser-induced prostatectomy: a critical evaluation. J Endourol. Oct. 1996;10(5):463-7. Case-series. [pmid: 8905495].
741 Chavis PS, Tabbara KF. Demyelination of retinal myelinated nerve fibers in Behcet's disease. Doc Ophthalmol. 1998;95(2):157-64. Case-reports. [pmid: 10431799].
742 Cheater F. Promoting urinary continence (continuing education credit). Nurs Stand. Jul 10. 1996;10(42):47-51. quiz 3–4. Case Reports. [pmid: 8718286].
743 Cheetham MJ, Kamm MA, Phillips RK. Topical phenylephrine increases anal canal resting pressure in patients with faecal incontinence. Gut. Mar. 2001;48(3):356-9. Not eligible outcomes. [pmid: 11171825]. [pmcid: 1760141].
744 Cheetham MJ, Mortensen NJ, Nystrom PO, et al. Persistent pain and faecal urgency after stapled haemorrhoidectomy. Lancet. Aug 26. 2000;356(9231):730-3. No associative hypothesis tested. [pmid: 11085693].
745 Chelvanayagam S, Norton C. Quality of life with faecal continence problems. Nurs Times. Aug 3. 2000;96(31 Suppl):15-7. Comment. [pmid: 11963697].
746 Chelvanayagam S, Stern J. Using therapeutic groups to support women with faecal incontinence. Br J Nurs. Feb 22–Mar 7. 2007;16(4):214-8. No associative hypothesis tested. [pmid: 17363851].
747 Chen B, Wen Y, Polan ML. Elastolytic activity in women with stress urinary incontinence and pelvic organ prolapse. Neurourol Urodyn. 2004;23(2):119-26. Not eligible outcomes. [pmid: 14983422].
748 Chen B, Wen Y, Yu X, et al. Elastin metabolism in pelvic tissues: is it modulated by reproductive hormones?. Am J Obstet Gynecol. May. 2005;192(5):1605-13. Not eligible outcomes. [pmid: 15902165].
749 Chen B, Wen Y, Zhang Z, et al. Microarray analysis of differentially expressed genes in vaginal tissues from women with stress urinary incontinence compared with asymptomatic women. Hum Reprod. Jan. 2006;21(1):22-9. Not eligible outcomes. [pmid: 16126751].
750 Chen BH, Wen Y, Li H, et al. Collagen metabolism and turnover in women with stress urinary incontinence and pelvic prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):80-7. discussion 7. Not eligible outcomes. [pmid: 12054187].
751 Chen CF, Chang MC, Liu CL, et al. Acute noncontiguous multiple-level thoracic disc herniations with myelopathy: a case report. Spine. Apr 15. 2004;29(8):E157-60. Case-reports. [pmid: 15083003].
752 Chen CH, Lee YH, Tzeng WS, et al. A patient with urgency, frequency, and low serum C reactive protein concentration. Postgrad Med J. Feb. 2005;81(952):139-40. Case Reports. [pmid: 15701752]. [pmcid: 1743210].
753 Chen GD, Lin LY, Gardner JD. The results of laparoscopic adhesiolysis for intractable urinary frequency. J Urol. Nov. 1997;158(5):1714-6. Not eligible target population. [pmid: 9334585].
754 Chen H, Humphreys MS, Kettlewell MG, et al. Anal ultrasound predicts the response to nonoperative treatment of fecal incontinence in men. Ann Surg. May. 1999;229(5):739-43. discussion 43–4. Case-series. [pmid: 10235533]. [pmcid: 1420819].
755 Chen HH, Iroatulam A, Alabaz O, et al. Associations of defecography and physiologic findings in male patients with rectocele. Tech Coloproctol. Dec. 2001;5(3):157-61. Not eligible outcomes. [pmid: 11875683].
756 Chen HY, Huang YL, Hung YC, et al. Evaluation of stress urinary incontinence by computer-aided vector-based perineal ultrasound. Acta Obstet Gynecol Scand. 2006;85(10):1259-64. Not eligible outcomes. [pmid: 17068687].
757 Chen JS, March LM, Schwarz J, et al. A multivariate regression model predicted falls in residents living in intermediate hostel care. J Clin Epidemiol. May. 2005;58(5):503-8. Not eligible outcomes. [pmid: 15845337].
758 Chen KK, Chang LS, Chen MT. Neobladder construction using completely detubularized sigmoid colon after radical cystoprostatectomy. J Urol. Aug. 1991;146(2):311-5. Case-series. [pmid: 1856923].
759 Chen KK, Chang LS, Chen MT, et al. Clinical experience of Kock pouch continent urinary diversion. Urology. Apr. 1990;35(4):317-20. Case-series. [pmid: 2321324].
760 Chen TY, Ponsot Y, Carmel M, et al. Multi-centre study of intraurethral valve-pump catheter in women with a hypocontractile or acontractile bladder. Eur Urol. Oct. 2005;48(4):628-33. Not eligible target population. [pmid: 15964124].
761 Chen Y, DeSautel M, Anderson A, et al. Collagen synthesis is not altered in women with stress urinary incontinence. Neurourol Urodyn. 2004;23(4):367-73. Not eligible outcomes. [pmid: 15227656].
762 Cheong DM, Vaccaro CA, Salanga VD, et al. Electrodiagnostic evaluation of fecal incontinence. Muscle Nerve. Jun. 1995;18(6):612-9. Not eligible outcomes. [pmid: 7753124].
763 Chester F. Promoting urinary continence (continuing education credit). Nurs Stand. May 12–18. 1993;7(34):31-6. Case Reports. [pmid: 8518164].
764 Chew SB, Tindal DS. Colonic J-pouch as a neorectum: functional assessment. Aust N Z J Surg. Sep. 1997;67(9):607-10. Case-series. [pmid: 9322696].
765 Chew SS, Rieger NA. Transperineal repair of obstetric-related anovaginal fistula. Aust N Z J Obstet Gynaecol. Feb. 2004;44(1):68-71. Case-series. [pmid: 15089873].
766 Chiara G, Piccioni V, Perino M, et al. Psychological investigation in female patients suffering from urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(2):73-7. Not eligible outcomes. [pmid: 9694134].
767 Chiarelli P, Brown WJ. Leaking urine in Australian women: prevalence and associated conditions. Women Health. 1999;29(1):1-13. Not eligible level of evidence.
768 Chiarelli P, Campbell E. Incontinence during pregnancy. Prevalence and opportunities for continence promotion. Aust N Z J Obstet Gynaecol. Feb. 1997;37(1):66-73. Not eligible level of evidence. [pmid: 9075550].
769 Chiarelli P, Murphy B, Cockburn J. Women's knowledge, practises, and intentions regarding correct pelvic floor exercises. Neurourol Urodyn. 2003;22(3):246-9. Not eligible outcomes. [pmid: 12707876].
770 Chiarioni G, Bassotti G, Stanganini S, et al. Sensory retraining is key to biofeedback therapy for formed stool fecal incontinence. Am J Gastroenterol. Jan. 2002;97(1):109-17. Not eligible target population. [pmid: 11808933].
771 Chiarioni G, Scattolini C, Bonfante F, et al. Liquid stool incontinence with severe urgency: anorectal function and effective biofeedback treatment. Gut. Nov. 1993;34(11):1576-80. Not eligible outcomes. [pmid: 8244147]. [pmcid: 1374425].
772 Chien GW, Tawadroas M, Kaptein JS, et al. Surgical treatment for stress urinary incontinence with urethral hypermobility: what is the best approach?. World J Urol. Sep. 2002;20(4):234-9. Case-series. [pmid: 12215853].
773 Chin HY, Chen MC, Liu YH, et al. Postpartum urinary incontinence: a comparison of vaginal delivery, elective, and emergent cesarean section. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2006;17(6):631-5. Not eligible level of evidence. [pmid: 16568215].
774 Chin JL, McLoughlin RF, Downey DB. Three-dimensional ultrasound and magnetic resonance imaging of pelvic anatomy: potential for complications from minimally invasive procedures. J Endourol. Jul–Aug. 1999;13(6):451-9. Case-series. [pmid: 10479014].
775 Chiou RK, Grune M, Rosinsky D, et al. Repair of extensive traumatic membranous urethral disruption with endourethroplasty and artificial sphincter: case report. J Endourol. Dec. 1995;9(6):509-12. Case-reports. [pmid: 8775085].
776 Chiverton PA, Wells TJ, Brink CA, et al. Psychological factors associated with urinary incontinence. Clin Nurse Spec. Sep. 1996;10(5):229-33. Not eligible outcomes. [pmid: 9069824].
777 Cho CY, Alessi CA, Cho M, et al. The association between chronic illness and functional change among participants in a comprehensive geriatric assessment program. J Am Geriatr Soc. Jun. 1998;46(6):677-82. Not eligible outcomes. [pmid: 9625181].
778 Choe JM. Preventing urethral obstruction using the 6-point fixation and weight-adjusted spacing nomogram during sling surgery. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):122-8. Not eligible target population. [pmid: 11374510].
779 Choe JM. Pubovaginal sling surgery without using abdominal leak point pressure: an outcomes analysis. Adv Exp Med Biol. 2003;539(Pt A):467-80. Not eligible outcomes. [pmid: 15088923].
780 Choe JM, Battino BS, Bell TE. Retrograde perfusion sphincterometry with a flexible cystoscope: method of troubleshooting the AMS 800. Urology. Aug 1. 2000;56(2):317-9. Case-series. [pmid: 10925103].
781 Choe JM, Gallo ML, Staskin DR. A provocative maneuver to elicit cystometric instability: measuring instability at maximum infusion. J Urol. May. 1999;161(5):1541-4. Not eligible outcomes. [pmid: 10210392].
782 Choe JM, Ogan K, Bennett S. Antibacterial mesh sling: a prospective outcome analysis. Urology. Apr. 2000;55(4):515-20. Case-series. [pmid: 10736494].
783 Choe JM, Staskin DR. Gore-Tex patch sling: 7 years later. Urology. Oct. 1999;54(4):641-6. Case-series. [pmid: 10510921].
784 Choi JS, Hwang YH, Salum MR, et al. Outcome and management of patients with large rectoanal intussusception. Am J Gastroenterol. Mar. 2001;96(3):740-4. Case-series. [pmid: 11280544].
785 Choo MS, Song C, Kim JH, et al. Changes in overactive bladder symptoms after discontinuation of successful 3-month treatment with an antimuscarinic agent: a prospective trial. J Urol. Jul. 2005;174(1):201-4. Not eligible target population. [pmid: 15947627].
786 Choo R, Hruby G, Hong J, et al. Positive resection margin and/or pathologic T3 adenocarcinoma of prostate with undetectable postoperative prostate-specific antigen after radical prostatectomy: to irradiate or not?. Int J Radiat Oncol Biol Phys. Mar 1. 2002;52(3):674-80. Case-series. [pmid: 11849789].
787 Chou EC, Flisser AJ, Panagopoulos G, et al. Effective treatment for mixed urinary incontinence with a pubovaginal sling. J Urol. Aug. 2003;170(2 Pt 1):494-7. Case-series. [pmid: 12853807].
788 Chou Q, Weber AM, Piedmonte MR. Clinical presentation of enterocele. Obstet Gynecol. Oct. 2000;96(4):599-603. Not eligible level of evidence. [pmid: 11004366].
789 Chou TP, Gorton E, Stanton SL, et al. Can uroflowmetry patterns in women be reliably interpreted?. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2000;11(3):142-7. Not eligible outcomes. [pmid: 11484741].
790 Chou YC, Yu KJ. Entrapped vaginal pessary presented with frequency and urge incontinence. J Chin Med Assoc. Mar. 2003;66(3):181-3. Case-reports. [pmid: 12779040].
791 Chow SH, LaSalle MD, Rosenberg GS. Urinary incontinence secondary to a vaginal pessary. Urology. Mar. 1997;49(3):458-9. Case Reports. [pmid: 9123717].
792 Christensen P, Buntzen S, Krogh K, et al. Ileal neoappendicostomy for antegrade colonic irrigation. Br J Surg. Dec. 2001;88(12):1637-8. Case-series. [pmid: 11736978].
793 Christensen P, Kvitzau B, Krogh K, et al. Neurogenic colorectal dysfunction - use of new antegrade and retrograde colonic wash-out methods. Spinal Cord. Apr. 2000;38(4):255-61. Not eligible target population. [pmid: 10822397].
794 Christensen P, Olsen N, Krogh K, et al. Scintigraphic assessment of retrograde colonic washout in fecal incontinence and constipation. Dis Colon Rectum. Jan. 2003;46(1):68-76. Not eligible outcomes. [pmid: 12544524].
795 Christensen P, Olsen N, Krogh K, et al. Scintigraphic assessment of antegrade colonic irrigation through an appendicostomy or a neoappendicostomy. Br J Surg. Oct. 2002;89(10):1275-80. Case-series. [pmid: 12296896].
796 Christiansen J. Advances in the surgical management of anal incontinence. Chirurgie. 1992;118(5):277-82. discussion 82–3. Case-series. [pmid: 1341282].
797 Christiansen J, Hansen CR, Rasmussen O. Bilateral gluteus maximus transposition for anal incontinence. Br J Surg. Jul. 1995;82(7):903-5. Case-series. [pmid: 7648103].
798 Christiansen J, Hesselfeldt P, Sorensen M. Treatment of internal rectal intussusception in patients with chronic constipation. Scand J Gastroenterol. May. 1995;30(5):470-2. Case-series. [pmid: 7638574].
799 Christiansen J, Rasmussen OO, Lindorff-Larsen K. Dynamic graciloplasty for severe anal incontinence. Br J Surg. Jan. 1998;85(1):88-91. Case-series. [pmid: 9462392].
800 Christiansen J, Rasmussen OO, Lindorff-Larsen K. Long-term results of artificial anal sphincter implantation for severe anal incontinence. Ann Surg. Jul. 1999;230(1):45-8. Case-series. [pmid: 10400035]. [pmcid: 1420843].
801 Christiansen J, Roed-Petersen K. Clinical assessment of the anal continence plug. Dis Colon Rectum. Aug. 1993;36(8):740-2. Case-series. [pmid: 8348862].
802 Christiansen J, Ronholt C. Treatment of recurrent high anal fistula by total excision and primary sphincter reconstruction. Int J Colorectal Dis. 1995;10(4):207-9. Case-series. [pmid: 8568405].
803 Christiansen J, Sorensen M, Rasmussen OO. Gracilis muscle transposition for faecal incontinence. Br J Surg. Sep. 1990;77(9):1039-40. Case-reports. [pmid: 2207570].
804 Christiansen J, Sparso B. Treatment of anal incontinence by an implantable prosthetic anal sphincter. Ann Surg. Apr. 1992;215(4):383-6. Case-series. [pmid: 1558420]. [pmcid: 1242456].
805 Christie D, Denham J, Steigler A, et al. Delayed rectal and urinary symptomatology in patients treated for prostate cancer by radiotherapy with or without short term neo-adjuvant androgen deprivation. Radiother Oncol. Nov. 2005;77(2):117-25. Not eligible outcomes. [pmid: 16271786].
806 Chu LW, Pei CK. Risk factors for early emergency hospital readmission in elderly medical patients. Gerontology. Jul–Aug. 1999;45(4):220-6. Not eligible outcomes. [pmid: 10394080].
807 Chua JJ, Tan PK, Seow WT. Leptomeningeal metastasis with urological presentation. Singapore Med J. Jun. 1997;38(6):266-7. Case-reports. [pmid: 9294342].
808 Chua K, Chuo A, Kong KH. Urinary incontinence after traumatic brain injury: incidence, outcomes and correlates. Brain Inj. Jun. 2003;17(6):469-78. Case-series. [pmid: 12745703].
809 Chua KS, Kong KH. Functional outcome in brain stem stroke patients after rehabilitation. Arch Phys Med Rehabil. Feb. 1996;77(2):194-7. Case-series. [pmid: 8607746].
810 Chuang TY, Yu KJ, Penn IW, et al. Neurourological changes before and after radical hysterectomy in patients with cervical cancer. Acta Obstet Gynecol Scand. Oct. 2003;82(10):954-9. Case-series. [pmid: 12956847].
811 Chun AB, Rose S, Mitrani C, et al. Anal sphincter structure and function in homosexual males engaging in anoreceptive intercourse. Am J Gastroenterol. Mar. 1997;92(3):465-8. Not eligible outcomes. [pmid: 9068471].
812 Chung BS, Lee T, Kim JS, et al. Occult intraperitoneal bladder injury after a tension-free vaginal tape procedure. Yonsei Med J. Dec 31. 2005;46(6):874-6. Case Reports. [pmid: 16385669].
813 Chung MK, Chung RP. Comparison of laparoscopic Burch and tension-free vaginal tape in treating stress urinary incontinence in obese patients. Jsls. Jan–Mar. 2002;6(1):17-21. Case-series. [pmid: 12002291].
814 Chung SY, Franks M, Smith CP, et al. Technique of combined pubovaginal sling and cystocele repair using a single piece of cadaveric dermal graft. Urology. Apr. 2002;59(4):538-41. Case-series. [pmid: 11927309].
815 Cimentepe E, Unsal A, Saglam R. Randomized clinical trial comparing transurethral needle ablation with transurethral resection of the prostate for the treatment of benign prostatic hyperplasia: results at 18 months. J Endourol. Mar. 2003;17(2):103-7. Not eligible exposure. [pmid: 12689404].
816 Cimic J, Meuleman EJ, Oosterhof GO, et al. Urological complications in renal transplantation. A comparison between living-related and cadaveric grafts. Eur Urol. 1997;31(4):433-5. Not eligible level of evidence. [pmid: 9187903].
817 Cindolo L, Salzano L, Rota G, et al. Tension-free transobturator approach for female stress urinary incontinence. Minerva Urol Nefrol. Mar. 2004;56(1):89-98. Case-series. [pmid: 15195034].
818 Cirocco WC, Brown AC. Anterior resection for the treatment of rectal prolapse: a 20-year experience. Am Surg. Apr. 1993;59(4):265-9. Case-series. [pmid: 8489090].
819 Cisternino A, Passerini-Glazel G. Bladder dysfunction in children. Scand J Urol Nephrol Suppl. 1995;173:25-8. discussion 9. Not eligible target population. [pmid: 8719562].
820 Citterio A, Franceschini M, Spizzichino L, et al. Nontraumatic spinal cord injury: an Italian survey. Arch Phys Med Rehabil. Sep. 2004;85(9):1483-7. Not eligible target population. [pmid: 15375821].
821 Clague MB, Heald RJ. Achievement of stomal continence in one-third of colostomies by use of a new disposable plug. Surg Gynecol Obstet. May. 1990;170(5):390-4. Case-series. [pmid: 2183370].
822 Clancy B, Malone-Lee J. Reducing the leakage of body-worn incontinence pads. J Adv Nurs. Feb. 1991;16(2):187-93. Not eligible outcomes. [pmid: 2013661].
823 Clark A, Romm J. Effect of urinary incontinence on sexual activity in women. J Reprod Med. Sep. 1993;38(9):679-83. Not eligible outcomes. [pmid: 8254588].
824 Clark AL, Gregory T, Smith VJ, et al. Epidemiologic evaluation of reoperation for surgically treated pelvic organ prolapse and urinary incontinence. Am J Obstet Gynecol. Nov. 2003;189(5):1261-7. Not eligible level of evidence. [pmid: 14634551].
825 Clark JA, Bokhour BG, Inui TS, et al. Measuring patients' perceptions of the outcomes of treatment for early prostate cancer. Med Care. Aug. 2003;41(8):923-36. Not eligible outcomes. [pmid: 12886172].
826 Clark JA, Inui TS, Silliman RA, et al. Patients' perceptions of quality of life after treatment for early prostate cancer. J Clin Oncol. Oct 15. 2003;21(20):3777-84. Not eligible outcomes. [pmid: 14551296].
827 Clark JA, Talcott JA. Symptom indexes to assess outcomes of treatment for early prostate cancer. Med Care. Oct. 2001;39(10):1118-30. Not eligible outcomes. [pmid: 11567174].
828 Clark MH, Benson JT. Fecal incontinence and the menstrual cycle: a case report. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):344-5. Case Reports. [pmid: 10543345].
829 Clarke-O'Neill S, Pettersson L, Fader M, et al. A multicenter comparative evaluation: disposable pads for women with light incontinence. J Wound Ostomy Continence Nurs. Jan–Feb. 2004;31(1):32-42. Not eligible outcomes. [pmid: 15128093].
830 Clarke-O'Neill S, Pettersson L, Fader M, et al. A multicentre comparative evaluation: washable pants with an integral pad for light incontinence. J Clin Nurs. Jan. 2002;11(1):79-89. Not eligible outcomes. [pmid: 11845759].
831 Clemens JQ, Stern JA, Bushman WA, et al. Long-term results of the Stamey bladder neck suspension: direct comparison with the Marshall-Marchetti-Krantz procedure. J Urol. Aug. 1998;160(2):372-6. Not eligible outcomes. [pmid: 9679880].
832 Clemesha L, Davies E. Educating home carers on faecal continence in people with dementia. Nurs Stand. May 5–11. 2004;18(34):33-40. Not eligible target population.
833 Clemons JL, Aguilar VC, Sokol ER, et al. Suburethral sling treatment of occult stress incontinence and intrinsic sphincter deficiency in women with severe vaginal prolapse of the anterior vs posterior/apical compartment. Am J Obstet Gynecol. May. 2005;192(5):1566-72. Case-series. [pmid: 15902159].
834 Clemons JL, Aguilar VC, Tillinghast TA, et al. Patient satisfaction and changes in prolapse and urinary symptoms in women who were fitted successfully with a pessary for pelvic organ prolapse. Am J Obstet Gynecol. Apr. 2004;190(4):1025-9. Not eligible outcomes. [pmid: 15118635].
835 Clever K, Smith G, Bowser C, et al. Evaluating the efficacy of a uniquely delivered skin protectant and its effect on the formation of sacral/buttock pressure ulcers. Ostomy Wound Manage. Dec. 2002;48(12):60-7. Not eligible outcomes. [pmid: 12490754].
836 Clow WM, Joannides T, Saleem AK, et al. An unusual cause of postmenopausal bleeding and incontinence of urine: primary lymphoma of the vagina. Br J Obstet Gynaecol. Feb. 1995;102(2):164-5. Case Reports. [pmid: 7756212].
837 Clyne OJ, O'Sullivan O, Flood HD. Pubovaginal sling for urodynamic stress incontinence: effect on patient quality of life. Ir Med J. Mar. 2005;98(3):75-7. Case-series. [pmid: 15869063].
838 Coakley FV, Eberhardt S, Kattan MW, et al. Urinary continence after radical retropubic prostatectomy: relationship with membranous urethral length on preoperative endorectal magnetic resonance imaging. J Urol. Sep. 2002;168(3):1032-5. Case-Series. [pmid: 12187216].
839 Cobb WS, Lokey JS, Schwab DP, et al. Hand-assisted laparoscopic colectomy: a single-institution experience. Am Surg. Jul. 2003;69(7):578-80. Case-series. [pmid: 12889620].
840 Cochran A. Fatal attraction: Foley catheters. Ostomy Wound Manage 1991 Sep–Oct; 36:40–1, 3–4. Case-reports
841 Cochran A. Don't ask, don't tell: the incontinence conspiracy. Manag Care Q. Winter. 2000;8(1):44-52. Comment. [pmid: 11009733].
842 Cochran I, Flynn CA, Goetz G, et al. Stroke care—piecing together the long-term picture. Nursing. Jun. 1994;24(6):34-41. quiz 2. Case Reports. [pmid: 8008277].
843 Cochrane DD, Irwin B, Chambers K. Clinical outcomes that fetal surgery for myelomeningocele needs to achieve. Eur J Pediatr Surg. Dec. 2001;11(Suppl 1):S18-20. Not eligible target population. [pmid: 11813128].
844 Cockell SJ, Oates-Johnson T, Gilmour DT, et al. Postpartum flatal and Fecal Incontinence Quality-of-Life Scale: a disease- and population-specific measure. Qual Health Res. Oct. 2003;13(8):1132-44. Case-series. [pmid: 14556423].
845 Coffey SW, Wilder E, Majsak MJ, et al. The effects of a progressive exercise program with surface electromyographic biofeedback on an adult with fecal incontinence. Phys Ther. Aug. 2002;82(8):798-811. Case-reports. [pmid: 12147009].
846 Cogan SL, Weber AM, Hammel JP. Is urethral mobility really being assessed by the pelvic organ prolapse quantification (POP-Q) system?. Obstet Gynecol. Mar. 2002;99(3):473-6. Not eligible outcomes. [pmid: 11864676].
847 Cohen HA, Abarbanel J, Ashkenasi A, et al. Urodynamic manifestations associated with Ramsay-Hunt syndrome. Case report. Scand J Urol Nephrol. 1993;27(1):129-31. Case-reports. [pmid: 8493462].
848 Cohen SJ, Robinson D, Dugan E, et al. Communication between older adults and their physicians about urinary incontinence. J Gerontol A Biol Sci Med Sci. Jan. 1999;54(1):M34-7. Not eligible level of evidence. [pmid: 10026660].
849 Cohn JH, El-Galley R. Radical prostatectomy in a community practice. J Urol. Jan. 2002;167(1):224-8. Case Series. [pmid: 11743311].
850 Col C, Hasdemir O, Yalcin E, et al. The assessment of urinary function following extended lymph node dissection for colorectal cancer. Eur J Surg Oncol. Apr. 2005;31(3):237-41. Not eligible level of evidence. [pmid: 15780557].
851 Colakoglu M, Capar M, Kilic M, et al. A new needle suspension procedure for genuine stress incontinence and anterior vaginal wall prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):64-7. discussion 7–8. Case-series. [pmid: 8798088].
852 Cole EE, Adams MC, Brock JW 3rd, et al. Outcome of continence procedures in the pediatric patient: a single institutional experience. J Urol. Aug. 2003;170(2 Pt 1):560-3. discussion 3. Not eligible target population. [pmid: 12853830].
853 Cole EE, Kaufman MR, Scarpero HM, et al. The effects of isolated posterior compartment defects on lower urinary tract symptoms and urodynamic findings. BJU Int. May. 2006;97(5):1024-6. Case-series. [pmid: 16643484].
854 Colley W. Products to help men manage incontinence. Nurs Times. Oct 22–28. 2002;98(43):52-4. Comment. [pmid: 12432732].
855 Colley W. Developing continence services through partnership. Nurs Times. Apr 23–29. 2002;98(17):63-4. Comment. [pmid: 12008271].
856 Colley W. Continence services in a changing NHS. Nurs Times. Apr 23–29. 2002;98(17):58-9. Comment. [pmid: 12008269].
857 Collinet P, Belot F, Debodinance P, et al. Transvaginal mesh technique for pelvic organ prolapse repair: mesh exposure management and risk factors. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):315-20. Not eligible outcomes. [pmid: 16228121].
858 Colling J, McCreedy M, Owen T. Urinary tract infection rates among incontinent nursing home and community dwelling elderly. Urol Nurs. Sep. 1994;14(3):117-9. Not eligible outcomes. [pmid: 7732412].
859 Colling J, Owen TR, McCreedy M, et al. The effects of a continence program on frail community-dwelling elderly persons. Urol Nurs 2003 Apr; 23(2):117–22, 27–31. Case-series
860 Colling JC, Owen TR, McCreedy MR. Urine volumes and voiding patterns among incontinent nursing home residents. Residents at highest risk for dehydration are often the most difficult to track. Geriatr Nurs. Jul–Aug. 1994;15(4):188-92. Not eligible level of evidence. [pmid: 8039731].
861 Collings S, Norton C. Women's experiences of faecal incontinence: a study. Br J Community Nurs. Dec. 2004;9(12):520-3. No associative hypothesis tested. [pmid: 15655485].
862 Coloby P, Gattegno B, Fourcade RO, et al. Bladder reconstruction with ileum after cystoprostatectomy for bladder cancer: analysis of the micturition and continence of 44 consecutive patients. Jpn J Clin Oncol. Apr. 1992;22(2):122-30. Case-series. [pmid: 1619779].
863 Colombo T, Augustin H, Breinl E, et al. The use of polydimethylsiloxane in the treatment of incontinence after radical prostatectomy. Br J Urol. Dec. 1997;80(6):923-6. Case-series. [pmid: 9439411].
864 Colquhoun P, Kaiser R, Weiss EG, et al. Correlating the Fecal Incontinence Quality-of-Life Score and the SF-36 to a proposed Ostomy Function Index in patients with a stoma. Ostomy Wound Manage. Dec. 2006;52(12):68-74. Not eligible outcomes.
865 Comiter CV. The male sling for stress urinary incontinence: a prospective study. J Urol. Feb. 2002;167(2 Pt 1):597-601. Case-series. [pmid: 11792925].
866 Comiter CV. The male perineal sling: intermediate-term results. Neurourol Urodyn. 2005;24(7):648-53. Case-series. [pmid: 16167352].
867 Comiter CV, Colegrove PM. High rate of vaginal extrusion of silicone-coated polyester sling. Urology. Jun. 2004;63(6):1066-70. Not eligible target population. [pmid: 15183951].
868 Comiter CV, Sullivan MP, Yalla SV. Retrograde leak point pressure for evaluating postradical prostatectomy incontinence. Urology. Feb. 1997;49(2):231-6. Case-series. [pmid: 9037285].
869 Comiter CV, Sullivan MP, Yalla SV. Correlation among maximal urethral closure pressure, retrograde leak point pressure, and abdominal leak point pressure in men with postprostatectomy stress incontinence. Urology. Jul. 2003;62(1):75-8. Not eligible outcomes. [pmid: 12837426].
870 Conaghan P, Farouk R. Sacral nerve stimulation can be successful in patients with ultrasound evidence of external anal sphincter disruption. Dis Colon Rectum. Aug. 2005;48(8):1610-4. Case-series. [pmid: 15937623].
871 Connell K, Guess MK, La Combe J, et al. Evaluation of the role of pudendal nerve integrity in female sexual function using noninvasive techniques. Am J Obstet Gynecol. May. 2005;192(5):1712-7. Not eligible outcomes. [pmid: 15902183].
872 Connolly TP. Necrotizing surgical site infection after tension-free vaginal tape. Obstet Gynecol. Dec. 2004;104(6):1275-6. Case-reports. [pmid: 15572489].
873 Connor JP, Betrus G, Fleming P, et al. Early cystometrograms can predict the response to intravesical instillation of oxybutynin chloride in myelomeningocele patients. J Urol. Apr. 1994;151(4):1045-7. Case-series. [pmid: 8126787].
874 Constantini E, Mearini L, Biscotto S, et al. Impact of different sized catheters on pressure-flow studies in women with lower urinary tract symptoms. Neurourol Urodyn. 2005;24(2):106-10. Not eligible exposure. [pmid: 15616966].
875 Coolen JC, Florisson JM, Bissett IP, et al. Evaluation of knowledge and anxiety level of patients visiting the colorectal pelvic floor clinic. Colorectal Dis. Mar. 2006;8(3):208-11. Not eligible outcomes. [pmid: 16466561].
876 Coombes GM, Millard RJ. Urinary urge incontinence: randomised crossover trials of penthienate versus placebo and propantheline. Med J Aust. Nov 4. 1996;165(9):473-6. Not eligible exposure. [pmid: 8937366].
877 Cooper P, Gray D. Comparison of two skin care regimes for incontinence. Br J Nurs 2001 Mar; 10(6 Suppl):S6, S8, S10 passim. Not eligible outcomes
878 Cooperberg MR, Master VA, Carroll PR. Health related quality of life significance of single pad urinary incontinence following radical prostatectomy. J Urol. Aug. 2003;170(2 Pt 1):512-5. Case-Series. [pmid: 12853811].
879 Copas P, Bukovsky A, Asbury B, et al. Estrogen, progesterone, and androgen receptor expression in levator ani muscle and fascia. J Womens Health Gend Based Med. Oct. 2001;10(8):785-95. Not eligible outcomes. [pmid: 11703891].
880 Cor A, Barbic M, Kralj B. Differences in the quantity of elastic fibres and collagen type I and type III in endopelvic fascia between women with stress urinary incontinence and controls. Urol Res. Jun. 2003;31(2):61-5. Not eligible outcomes. [pmid: 12677309].
881 Coran AG. A personal experience with 100 consecutive total colectomies and straight ileoanal endorectal pull-throughs for benign disease of the colon and rectum in children and adults. Ann Surg. Sep. 1990;212(3):242-7. discussion 7–8. Not eligible target population. [pmid: 2396880]. [pmcid: 1358148].
882 Corcos J, Casey R, Patrick A, et al. A double-blind randomized dose-response study comparing daily doses of 5, 10 and 15 mg controlled-release oxybutynin: balancing efficacy with severity of dry mouth. BJU Int. Mar. 2006;97(3):520-7. Not eligible exposure. [pmid: 16469019].
883 Corcos J, Fournier C. Periurethral collagen injection for the treatment of female stress urinary incontinence: 4-year follow-up results. Urology. Nov. 1999;54(5):815-8. No associative hypothesis tested. [pmid: 10565739].
884 Cornacchia M, Zenorini A, Perobelli S, et al. Prevalence of urinary incontinence in women with cystic fibrosis. BJU Int. Jul. 2001;88(1):44-8. Not eligible level of evidence. [pmid: 11446844].
885 Cornel EB, de Wit R, Witjes JA. Evaluation of early pelvic floor physiotherapy on the duration and degree of urinary incontinence after radical retropubic prostatectomy in a non-teaching hospital. World J Urol. Nov. 2005;23(5):353-5. Not eligible outcomes. [pmid: 16211421].
886 Cortes E, Singh K, Reid WM. Anorexia nervosa and pelvic floor dysfunction. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):254-5. discussion 5. Case Reports. [pmid: 14530837].
887 Cosimo O, Pierluigi P, Angelo ZM, et al. A clinical and urodynamic study of patients with varying degrees of cystocele. Maturitas. Jun. 1997;27(2):125-32. Not eligible target population. [pmid: 9255747].
888 Cosson M, Boukerrou M, Narducci F, et al. Long-term results of the Burch procedure combined with abdominal sacrocolpopexy for treatment of vault prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):104-7. Case-series. [pmid: 12851752].
889 Cosson M, Lambaudie E, Boukerrou M, et al. A biomechanical study of the strength of vaginal tissues. Results on 16 post-menopausal patients presenting with genital prolapse. Eur J Obstet Gynecol Reprod Biol. Feb 10. 2004;112(2):201-5. Not eligible outcomes. [pmid: 14746960].
890 Costa JA, Kreder KJ, Howe JR. Combined urinary and fecal diversion using a no bowel anastomosis technique. J Urol. May. 2002;167(5):2063-5. Case-series. [pmid: 11956439].
891 Costa P, Grise P, Droupy S, et al. Surgical treatment of female stress urinary incontinence with a trans-obturator-tape (T.O.T.) Uratape: short term results of a prospective multicentric study. Eur Urol. Jul. 2004;46(1):102-6. discussion 6–7. Not eligible target population. [pmid: 15183554].
892 Costantini E, Lombi R, Micheli C, et al. Colposacropexy with Gore-tex mesh in marked vaginal and uterovaginal prolapse. Eur Urol. Aug. 1998;34(2):111-7. Case-series. [pmid: 9693245].
893 Costantini E, Mearini L, Mearini E, et al. Assessing outcome after a modified vaginal wall sling for stress incontinence with intrinsic sphincter deficiency. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):138-46. discussion 46. Case-series. [pmid: 15789147].
894 Costantini E, Pajoncini C, Zucchi A, et al. Four-corner colposuspension: clinical and functional results. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):113-8. Case-series. [pmid: 12851754].
895 Costantini S, Mistrangelo E, Francioso R, et al. Vaginal versus transabdominal hysterectomy: is mode of hysterectomy to influence pelvic statics or is pelvic statics to influence mode of hysterectomy?. Acta Obstet Gynecol Scand. Apr. 2005;84(4):376-9. Case-series. [pmid: 15762969].
896 Costanzo ES, Antes LM, Christensen AJ. Behavioral and medical treatment of chronic polydipsia in a patient with schizophrenia and diabetes insipidus. Psychosom Med. Mar–Apr. 2004;66(2):283-6. Case-reports. [pmid: 15039516].
897 Couillard DR, Deckard-Janatpour KA, Stone AR. The vaginal wall sling: a compressive suspension procedure for recurrent incontinence in elderly patients. Urology. Feb. 1994;43(2):203-8. Case-series. [pmid: 8116116].
898 Couillard DR, Vapnek JM, Stone AR. Proximal artificial sphincter cuff repositioning for urethral atrophy incontinence. Urology. Apr. 1995;45(4):653-6. Not eligible target population. [pmid: 7716847].
899 Couzens S. The perioperative practitioner. Br J Perioper Nurs 2004 Jul; 14(7):317–8, 20–1; discussion 22–3. Case Reports
900 Coward RT, Horne C, Peek CW. Predicting nursing home admissions among incontinent older adults: a comparison of residential differences across six years. Gerontologist. Dec. 1995;35(6):732-43. Not eligible outcomes. [pmid: 8557201].
901 Coyne KS, Matza LS, Thompson CL, et al. Determining the importance of change in the overactive bladder questionnaire. J Urol. Aug. 2006;176(2):627-32. discussion 32. Not eligible outcomes. [pmid: 16813906].
902 Coyne KS, Payne C, Bhattacharyya SK, et al. The impact of urinary urgency and frequency on health-related quality of life in overactive bladder: results from a national community survey. Value Health. Jul–Aug. 2004;7(4):455-63. Not eligible outcomes. [pmid: 15449637].
903 Coyne KS, Zyczynski T, Margolis MK, et al. Validation of an overactive bladder awareness tool for use in primary care settings. Adv Ther. Jul–Aug. 2005;22(4):381-94. Not eligible outcomes. [pmid: 16418145].
904 Craggs MD. Objective measurement of bladder sensation: use of a new patient-activated device and response to neuromodulation. BJU Int. Sep. 2005;96(Suppl 1):29-36. Not eligible outcomes.
905 Craig DI. Spinal cord injury and pregnancy: the stories of two women. SCI Nurs. Dec. 1994;11(4):100-4. Case-reports. [pmid: 7777841].
906 Cramer EH, Jones P, Keenan NL, et al. Is naturopathy as effective as conventional therapy for treatment of menopausal symptoms?. J Altern Complement Med. Aug. 2003;9(4):529-38. Not eligible exposure. [pmid: 14499029].
907 Creasey GH, Dahlberg JE. Economic consequences of an implanted neuroprosthesis for bladder and bowel management. Arch Phys Med Rehabil. Nov. 2001;82(11):1520-5. Not eligible outcomes. [pmid: 11689970].
908 Creasey GH, Grill JH, Korsten M, et al. An implantable neuroprosthesis for restoring bladder and bowel control to patients with spinal cord injuries: a multicenter trial. Arch Phys Med Rehabil. Nov. 2001;82(11):1512-9. Case-series. [pmid: 11689969].
909 Cronje HS. Colposacrosuspension for severe genital prolapse. Int J Gynaecol Obstet. Apr. 2004;85(1):30-5. Case-series. [pmid: 15050464].
910 Cronje HS, De Beer JA, Bam R. The pathophysiology of an enterocele and its management. J Obstet Gynaecol. Jun. 2004;24(4):408-13. Case-series. [pmid: 15203582].
911 Crosbie JJ, Eguare E, McGovern B, et al. The influence of bladder filling on anorectal function. Colorectal Dis. May. 2003;5(3):251-5. Not eligible exposure. [pmid: 12780887].
912 Cross CA, Cespedes RD, McGuire EJ. Treatment results using pubovaginal slings in patients with large cystoceles and stress incontinence. J Urol. Aug. 1997;158(2):431-4. Case-series. [pmid: 9224317].
913 Cross CA, Cespedes RD, McGuire EJ. Our experience with pubovaginal slings in patients with stress urinary incontinence. J Urol. Apr. 1998;159(4):1195-8. Case-series. [pmid: 9507831].
914 Crossland J. Continence. Strictly personal. Nurs Times. Apr 13–19. 1994;90(15):74-6. Comment. [pmid: 8183714].
915 Crowder H. Incontinence: the secret problem. N Z Nurs J. Mar. 1991;84(2):19-21. No associative hypothesis tested. [pmid: 2011324].
916 Crowell MD, Lacy BE, Schettler VA, et al. Subtypes of anal incontinence associated with bowel dysfunction: clinical, physiologic, and psychosocial characterization. Dis Colon Rectum. Oct. 2004;47(10):1627-35. Case-series. [pmid: 15540291].
917 Cruikshank SH, Muniz M. Outcomes study: A comparison of cure rates in 695 patients undergoing sacrospinous ligament fixation alone and with other site-specific procedures—a 16-year study. Am J Obstet Gynecol. Jun. 2003;188(6):1509-12. discussion 12–5. Case-series. [pmid: 12824986].
918 Csata S, Repassy D. Ureter and bladder replacement following radical cystectomy. Acta Chir Hung. 1998;37(12):107-10. Case Reports. [pmid: 10196619].
919 Cucchi A. Sequential changes in voiding dynamics related to the development of detrusor instability in women with stress urinary incontinence. Neurourol Urodyn. 1999;18(2):73-80. Case-series. [pmid: 10081946].
920 Cucchi A, Siracusano S, Di Benedetto P, et al. Urgency of voiding and abdominal pressure transmission in women with mixed urinary incontinence. Neurourol Urodyn. 2004;23(1):43-7. Not eligible outcomes. [pmid: 14694456].
921 Cuesta MA, Meijer S, Derksen EJ, et al. Anal sphincter imaging in fecal incontinence using endosonography. Dis Colon Rectum. Jan. 1992;35(1):59-63. Not eligible outcomes. [pmid: 1733685].
922 Cugudda A, Terrone C, Crivellaro S, et al. Long-term results of Burch colposuspension and anterior colpoperineorraphy in the treatment of stress urinary incontinence and cystocele. Ann Urol (Paris). May. 2002;36(3):176-81. Case-series. [pmid: 12056090].
923 Culbert P, Gillett H, Ferguson A. Highly effective new oral therapy for faecal impaction. Br J Gen Pract. Sep. 1998;48(434):1599-600. Case-series. [pmid: 9830188]. [pmcid: 1313226].
924 Cullen JJ, Kelly KA. Prospectively evaluating anal sphincter function after ileal pouch-anal canal anastomosis. Am J Surg. Jun. 1994;167(6):558-61. Case-series. [pmid: 8209927].
925 Culligan PJ, Myers JA, Goldberg RP, et al. Elective cesarean section to prevent anal incontinence and brachial plexus injuries associated with macrosomia—a decision analysis. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):19-28. discussion Not eligible outcomes. [pmid: 15647962].
926 Cummings JM, Houston K. The treatment of urinary incontinence. Hosp Pract (Off Ed) 1994 Feb 15; 29(2):97–9, 103, 7. Comment
927 Cummings V, Holt R, van der Sloot C, et al. Costs and management of urinary incontinence in long-term care. J Wound Ostomy Continence Nurs. Jul. 1995;22(4):193-8. Not eligible outcomes. [pmid: 7627295].
928 Cundall JD, Gardiner A, Chin K, et al. Hyperbaric oxygen in the treatment of fecal incontinence secondary to pudendal neuropathy. Dis Colon Rectum. Nov. 2003;46(11):1549-54. Not eligible target population. [pmid: 14605578].
929 Cundiff GW, Bent AE. The contribution of urethrocystoscopy to evaluation of lower urinary tract dysfunction in women. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(6):307-11. Not eligible outcomes. [pmid: 9203477].
930 Cundiff GW, Weidner AC, Visco AG, et al. An anatomic and functional assessment of the discrete defect rectocele repair. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1451-6. discussion 6–7. Case-series. [pmid: 9855580].
931 Cunha DF, Frota RB, Arruda MS, et al. Pressure sores among malnourished necropsied adults—preliminary data. Rev Hosp Clin Fac Med Sao Paulo. May–Jun. 2000;55(3):79-82. Not eligible outcomes. [pmid: 10983009].
932 Cunningham RS. Clinical practice guideline use by oncology advanced practice nurses. Appl Nurs Res. Aug. 2006;19(3):126-33. Not eligible outcomes. [pmid: 16877191].
933 Cunsolo A, Bragaglia RB, Manara G, et al. Urogenital dysfunction after abdominoperineal resection for carcinoma of the rectum. Dis Colon Rectum. Nov. 1990;33(11):918-22. Case-series. [pmid: 2226076].
934 Curran FT, Hill GL. Results of 50 ileoanal J pouch operations. Aust N Z J Surg. Aug. 1990;60(8):579-83. Case-series. [pmid: 2167655].
935 Currie CJ, McEwan P, Poole CD, et al. The impact of the overactive bladder on health-related utility and quality of life. BJU Int. Jun. 2006;97(6):1267-72. Not eligible outcomes. [pmid: 16686724].
936 Currie I, Drutz HP, Deck J, et al. Adipose tissue and lipid droplet embolism following periurethral injection of autologous fat: case report and review of the literature. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(6):377-80. Case Reports. [pmid: 9609338].
937 Curry JI, Osborne A, Malone PS. The MACE procedure: experience in the United Kingdom. J Pediatr Surg. Feb. 1999;34(2):338-40. Not eligible target population. [pmid: 10052818].
938 Cuschieri A, Shimi SM, Vander Velpen G, et al. Laparoscopic prosthesis fixation rectopexy for complete rectal prolapse. Br J Surg. Jan. 1994;81(1):138-9. Case-series. [pmid: 8313092].
939 Cutner A, Cardozo LD, Wise BG. The effects of pregnancy on previous incontinence surgery. Case report. Br J Obstet Gynaecol. Nov. 1991;98(11):1181-3. Case-reports. [pmid: 1760435].
940 Cuzzell JZ. Practical tips for incontinence. Home Care Provid. Dec. 1997;2(6):286-7. Comment. [pmid: 9451159].
941 Da Ros CT, Teloken C, Busatto WF Jr, et al. Endoscopic suspension of the prolapsed vaginal dome. Tech Urol. Mar. 1998;4(1):25-8. Case-series. [pmid: 9568773].
942 da Silva GM, Gurland B, Sleemi A, et al. Posterior vaginal wall prolapse does not correlate with fecal symptoms or objective measures of anorectal function. Am J Obstet Gynecol. Dec. 2006;195(6):1742-7. Not eligible level of evidence. [pmid: 17132476].
943 da Silva GM, Jorge JM, Belin B, et al. New surgical options for fecal incontinence in patients with imperforate anus. Dis Colon Rectum. Feb. 2004;47(2):204-9. Not eligible target population. [pmid: 15043291].
944 Daher N, Boulanger JC, Ulmsten U. Pre-pubic TVT: an alternative to classic TVT in selected patients with urinary stress incontinence. Eur J Obstet Gynecol Reprod Biol. Apr 25. 2003;107(2):205-7. Case-series. [pmid: 12648870].
945 Dahm P, Silverstein AD, Weizer AZ, et al. A longitudinal assessment of bowel related symptoms and fecal incontinence following radical perineal prostatectomy. J Urol. Jun. 2003;169(6):2220-4. Case-series. [pmid: 12771754].
946 Daley J, Delbanco TL, Hartman EE. An 89-year-old woman with urinary incontinence, 1 year later. Jama. Aug 27. 1997;278(8):679. Case-reports. [pmid: 9272902].
947 D'Alfonso A, Iovenitti P, Carta G. Urinary disorders during pregnancy and postpartum: our experience. Clin Exp Obstet Gynecol. 2006;33(1):23-5. Case-series. [pmid: 16761533].
948 Dalkin BL, Christopher BA, Shawler D. Health related quality of life outcomes after radical prostatectomy: attention to study design and the patient-based importance of single-surgeon studies. Urol Oncol. Jan–Feb. 2006;24(1):28-32. Case Series. [pmid: 16414489].
949 Dalkin BL, Wessells H, Cui H. A national survey of urinary and health related quality of life outcomes in men with an artificial urinary sphincter for post-radical prostatectomy incontinence. J Urol. Jan. 2003;169(1):237-9. Case Series. [pmid: 12478144].
950 Dallosso H. Lower urinary tract symptoms: why incidence rates are vital. Nurs Times. May 17–23. 2001;97(20):72. Not associative hypothesis tested. [pmid: 11962057].
951 Dallosso HM, Matthews RJ, McGrother CW, et al. An investigation into nonresponse bias in a postal survey on urinary symptoms. BJU Int. May. 2003;91(7):631-6. Not eligible level of evidence. [pmid: 12699474].
952 Dallosso HM, Matthews RJ, McGrother CW, et al. The association of diet and other lifestyle factors with the onset of overactive bladder: a longitudinal study in men. Public Health Nutr. Oct. 2004;7(7):885-91. Not eligible outcomes. [pmid: 15482614].
953 Dallosso HM, McGrother CW, Matthews RJ, et al. Nutrient composition of the diet and the development of overactive bladder: a longitudinal study in women. Neurourol Urodyn. 2004;23(3):204-10. Not eligible target population. [pmid: 15098215].
954 Damani N, Wilson SR. Nongynecologic applications of transvaginal US. Radiographics 1999 Oct; 19 Spec No:S179–200; quiz S65–6. Not eligible outcomes
955 Damon H, Bretones S, Henry L, et al. Long-term consequences of first vaginal delivery-induced anal sphincter defect. Dis Colon Rectum. Sep. 2005;48(9):1772-6. Not eligible outcomes. [pmid: 15981061].
956 Damon H, Dumas P, Mion F. Impact of anal incontinence and chronic constipation on quality of life. Gastroenterol Clin Biol. Jan. 2004;28(1):16-20. Not eligible outcomes. [pmid: 15041805].
957 Damon H, Henry L, Barth X, et al. Fecal incontinence in females with a past history of vaginal delivery: significance of anal sphincter defects detected by ultrasound. Dis Colon Rectum. Nov. 2002;45(11):1445-50. discussion 50–1. Not eligible outcomes. [pmid: 12432289].
958 Damon H, Henry L, Bretones S, et al. Postdelivery anal function in primiparous females: ultrasound and manometric study. Dis Colon Rectum. Apr. 2000;43(4):472-7. Not eligible outcomes. [pmid: 10789741].
959 Damon H, Henry L, Roman S, et al. Influence of rectal prolapse on the asymmetry of the anal sphincter in patients with anal incontinence. BMC Gastroenterol. Aug 19. 2003;3:23. Not eligible outcomes. [pmid: 12925237]. [pmcid: 194588].
960 Dandapat MC, Mishra JN, Das RP. Abdominal suture proctopexy for complete prolapse of rectum. J Indian Med Assoc. Dec. 1991;89(12):331-3. Case-series. [pmid: 1816311].
961 Danek A, Uttner I, Yoursry T, et al. Lyme neuroborreliosis disguised as normal pressure hydrocephalus. Neurology. Jun. 1996;46(6):1743-5. Case-reports. [pmid: 8649583].
962 Daneshgari F, Moore C, Frinjari H, et al. Patient related risk factors for recurrent stress urinary incontinence surgery in women treated at a tertiary care center. J Urol. Oct. 2006;176(4 Pt 1):1493-9. Not eligible level of evidence. [pmid: 16952667].
963 Darai E, Jeffry L, Deval B, et al. Results of tension-free vaginal tape in patients with or without vaginal hysterectomy. Eur J Obstet Gynecol Reprod Biol. Jul 10. 2002;103(2):163-7. Case-series. [pmid: 12069741].
964 Darkow T, Fontes CL, Williamson TE. Costs associated with the management of overactive bladder and related comorbidities. Pharmacotherapy. Apr. 2005;25(4):511-9. Not eligible outcomes. [pmid: 15977912].
965 Das A, Kennett K, Fraundorfer M, et al. Holmium laser resection of the prostate (HoLRP): 2-year follow-up data. Tech Urol. Dec. 2001;7(4):252-5. Case-Series. [pmid: 11763482].
966 Das AK, Carlson AM, Hull M. Improvement in depression and health-related quality of life after sacral nerve stimulation therapy for treatment of voiding dysfunction. Urology. Jul. 2004;64(1):62-8. Not eligible target population. [pmid: 15245937].
967 Das S. Dynamic suburethral suspension with pedicled external oblique aponeurosis in the management of female urinary incontinence. J Urol. Aug. 1999;162(2):469-73. Case-series. [pmid: 10411059].
968 Das S, Palmer JK. Laparoscopic colpo-suspension. J Urol. Sep. 1995;154(3):1119-21. Case-series. [pmid: 7637058].
969 Dattoli M, Wallner K, Sorace R, et al. 103Pd brachytherapy and external beam irradiation for clinically localized, high-risk prostatic carcinoma. Int J Radiat Oncol Biol Phys. Jul 15. 1996;35(5):875-9. Case-series. [pmid: 8751395].
970 David G, Durr A, Stevanin G, et al. Molecular and clinical correlations in autosomal dominant cerebellar ataxia with progressive macular dystrophy (SCA7). Hum Mol Genet. Feb. 1998;7(2):165-70. Not eligible outcomes. [pmid: 9425222].
971 David-Montefiore E, Garbin O, Hummel M, et al. Sacro-spinous ligament fixation peri-operative complications in 195 cases: visual approach versus digital approach of the sacro-spinous ligament. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2004;116(1):71-8. Case-series. [pmid: 15294372].
972 Davidson HA, Borrie MJ, Crilly RG. Copy task performance and urinary incontinence in Alzheimer's disease. J Am Geriatr Soc. May. 1991;39(5):467-71. Question 2. [pmid: 2022798].
973 Davidson PJ, van den Ouden D, Schroeder FH. Radical prostatectomy: prospective assessment of mortality and morbidity. Eur Urol. 1996;29(2):168-73. Case-Series. [pmid: 8647142].
974 Davies MC, Crouch NS, Woodhouse CR, et al. Congenital adrenal hyperplasia and lower urinary tract symptoms. BJU Int. Jun. 2005;95(9):1263-6. Not eligible level of evidence. [pmid: 15892813].
975 Davila GW, Daugherty CA, Sanders SW. A short-term, multicenter, randomized double-blind dose titration study of the efficacy and anticholinergic side effects of transdermal compared to immediate release oral oxybutynin treatment of patients with urge urinary incontinence. J Urol. Jul. 2001;166(1):140-5. Not eligible exposure. [pmid: 11435842].
976 Davila GW, Ghoniem GM, Kapoor DS, et al. Pelvic floor dysfunction management practice patterns: a survey of members of the International Urogynecological Association. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):319-25. Not eligible target population. [pmid: 12355293].
977 Davila GW, Neal D, Horbach N, et al. A bladder-neck support prosthesis for women with stress and mixed incontinence. Obstet Gynecol. Jun. 1999;93(6):938-42. Not eligible target population. [pmid: 10362158].
978 Davila GW, Ostermann KV. The bladder neck support prosthesis: a nonsurgical approach to stress incontinence in adult women. Am J Obstet Gynecol. Jul. 1994;171(1):206-11. Not eligible target population. [pmid: 8030700].
979 Davila GW, Stanford E, Korn A. Prospective trial of gasless laparoscopic Burch colposuspension using conventional surgical instruments. J Am Assoc Gynecol Laparosc. May. 2004;11(2):197-203. Not eligible target population. [pmid: 15200775].
980 Davis G, Sherman R, Wong MF, et al. Urinary incontinence among female soldiers. Mil Med. Mar. 1999;164(3):182-7. Not eligible level of evidence. [pmid: 10091490].
981 Davis JW, Schellhammer PF. Collagen mass in prostatic bed after radical retropubic prostatectomy. Urology. Jul. 1997;50(1):121. Case-reports. [pmid: 9218032].
982 Davis K, Kumar D, Poloniecki J. Preliminary evaluation of an injectable anal sphincter bulking agent (Durasphere) in the management of faecal incontinence. Aliment Pharmacol Ther. Jul 15. 2003;18(2):237-43. Case-series. [pmid: 12869085].
983 Davis K, Kumar D, Stanton SL, et al. Symptoms and anal sphincter morphology following primary repair of third-degree tears. Br J Surg. Dec. 2003;90(12):1573-9. Case-series. [pmid: 14648738].
984 Davis NS, Bavendam TG. Use of a urethral occlusion device for treatment of incontinence in a patient with heterotopic urinary diversion. Tech Urol. Sep. 2001;7(3):246-8. Case-reports. [pmid: 11575523].
985 Davison BJ, Goldenberg SL. Decisional regret and quality of life after participating in medical decision-making for early-stage prostate cancer. BJU Int. Jan. 2003;91(1):14-7. Not eligible outcomes. [pmid: 12614242].
986 Day PL. Findings of a three-year retrospective study to investigate prevalence and incidence of urinary incontinence and overactive bladder in a typical managed care setting. Pharm Pract Manag Q. Apr. 2000;20(1):1-11. Not eligible outcomes.
987 Dayton MT, Morrell DG. Factors associated with nighttime incontinence following ileoanal pullthrough. Am J Surg. Dec. 1991;162(6):599-602. Case-series. [pmid: 1670233].
988 de Aloysio D, Altieri P, Penacchioni P, et al. Premenopause-dependent changes. Gynecol Obstet Invest. 1996;42(2):120-7. Not eligible level of evidence. [pmid: 8878718].
989 De Deyn PP, Carrasco MM, Deberdt W, et al. Olanzapine versus placebo in the treatment of psychosis with or without associated behavioral disturbances in patients with Alzheimer's disease. Int J Geriatr Psychiatry. Feb. 2004;19(2):115-26. Not eligible exposure. [pmid: 14758577].
990 De Ganck J, Everaert K, Van Laecke E, et al. A high easy-to-treat complication rate is the price for a continent stoma. BJU Int. Aug. 2002;90(3):240-3. Case-series. [pmid: 12133058].
991 de Graaf EJ, Gilberts EC, Schouten WR. Role of segmental colonic transit time studies to select patients with slow transit constipation for partial left-sided or subtotal colectomy. Br J Surg. May. 1996;83(5):648-51. Not eligible outcomes. [pmid: 8689210].
992 de la Rosette JJ, Witjes WP, Schafer W, et al. Relationships between lower urinary tract symptoms and bladder outlet obstruction: results from the ICS-“BPH” study. Neurourol Urodyn. 1998;17(2):99-108. Not eligible outcomes. [pmid: 9514142].
993 de Leval J. Novel surgical technique for the treatment of female stress urinary incontinence: transobturator vaginal tape inside-out. Eur Urol. Dec. 2003;44(6):724-30. No associative hypothesis tested. [pmid: 14644127].
994 De Looze D, Van Laere M, De Muynck M, et al. Constipation and other chronic gastrointestinal problems in spinal cord injury patients. Spinal Cord. Jan. 1998;36(1):63-6. Case-series. [pmid: 9471141].
995 de Mooij Y, Burger MP, Schilthuis MS, et al. Partial urethral resection in the surgical treatment of vulvar cancer does not have a significant impact on urinary continence. A confirmation of an authority-based opinion. Int J Gynecol Cancer. Jan–Feb. 2007;17(1):294-7. Case-series. [pmid: 17291271].
996 de Parades V, Etienney I, Bauer P, et al. Formalin application in the treatment of chronic radiation-induced hemorrhagic proctitis—an effective but not risk-free procedure: a prospective study of 33 patients. Dis Colon Rectum. Aug. 2005;48(8):1535-41. Not eligible target population. [pmid: 15933799].
997 De Ridder D, Chandiramani V, Dasgupta P, et al. Intravesical capsaicin as a treatment for refractory detrusor hyperreflexia: a dual center study with long-term followup. J Urol. Dec. 1997;158(6):2087-92. Not eligible target population. [pmid: 9366318].
998 De Serres G, Shadmani R, Duval B, et al. Morbidity of pertussis in adolescents and adults. J Infect Dis. Jul. 2000;182(1):174-9. Not eligible target population. [pmid: 10882595].
999 de Stefani S, Liguori G, Ciampalini S, et al. AMS 800 artificial sphincter: an unusual case of circumscribed peritonitis due to prosthetic reservoir infection. Arch Esp Urol. May. 1999;52(4):412-5. Case-reports. [pmid: 10380335].
1000 de Tayrac R, Gervaise A, Chauveaud-Lambling A, et al. Combined genital prolapse repair reinforced with a polypropylene mesh and tension-free vaginal tape in women with genital prolapse and stress urinary incontinence: a retrospective case-control study with short-term follow-up. Acta Obstet Gynecol Scand. Oct. 2004;83(10):950-4. Not eligible target population. [pmid: 15453892].
1001 de Tayrac R, Picone O, Chauveaud-Lambling A, et al. A 2-year anatomical and functional assessment of transvaginal rectocele repair using a polypropylene mesh. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2006;17(2):100-5. Case Reports. [pmid: 15909075].
1002 de Tayrac R, Salet-Lizee D, Villet R. Comparison of anterior colporrhaphy versus Bologna procedure in women with genuine stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(1):36-9. Case-series. [pmid: 11999203].
1003 De Vocht TF, van Venrooij GE, Boon TA. Self-expanding stent insertion for urethral strictures: a 10-year follow-up. BJU Int. May. 2003;91(7):627-30. Not eligible target population. [pmid: 12699473].
1004 Dealey C. Pressure sores and incontinence: a study evaluating the use of topical agents in skin care. J Wound Care. Mar. 1995;4(3):103-5. Not eligible outcomes. [pmid: 7600345].
1005 Debaere C, Rigauts H, Steyaert L, et al. MR imaging of a diverticulum in a female urethra. J Belge Radiol. Dec. 1995;78(6):345-6. Case Reports. [pmid: 8576022].
1006 Decter RM. Use of the fascial sling for neurogenic incontinence: lessons learned. J Urol. Aug. 1993;150(2 Pt 2):683-6. Case-series. [pmid: 8326622].
1007 Deen KI. Faecal incontinence after vaginal delivery. Ceylon Med J. Mar. 2003;48(1):1-3. Question 2. [pmid: 12795009].
1008 Deen KI, Kumar D, Williams JG, et al. The prevalence of anal sphincter defects in faecal incontinence: a prospective endosonic study. Gut. May. 1993;34(5):685-8. Not eligible outcomes. [pmid: 8504972]. [pmcid: 1374190].
1009 Deen KI, Kumar D, Williams JG, et al. Anal sphincter defects. Correlation between endoanal ultrasound and surgery. Ann Surg. Aug. 1993;218(2):201-5. Not eligible outcomes. [pmid: 8343001]. [pmcid: 1242931].
1010 Deffieux X, Donnadieu AC, Porcher R, et al. Long-term results of tension-free vaginal tape for female urinary incontinence: Follow up over 6 years. Int J Urol. Jun. 2007;14(6):521-6. Not eligible level of evidence. [pmid: 17593097].
1011 Defloor T, Schoonhoven L, Katrien V, et al. Reliability of the European Pressure Ulcer Advisory Panel classification system. J Adv Nurs. Apr. 2006;54(2):189-98. Not eligible outcomes. [pmid: 16553705].
1012 Defraigne JO, Otto B, Sakalihasan N, et al. Spinal ischaemia after surgery for abdominal infrarenal aortic aneurysm. Diagnosis with nuclear magnetic resonance. Acta Chir Belg. Oct. 1997;97(5):250-6. Case Reports. [pmid: 9394968].
1013 Defreitas GA, Lemack GE, Zimmern PE, et al. Distinguishing neurogenic from non-neurogenic detrusor overactivity: a urodynamic assessment of lower urinary tract symptoms in patients with and without Parkinson's disease. Urology. Oct. 2003;62(4):651-5. Not eligible target population. [pmid: 14550436].
1014 Defreitas GA, Wilson TS, Zimmern PE, et al. Three-dimensional ultrasonography: an objective outcome tool to assess collagen distribution in women with stress urinary incontinence. Urology. Aug. 2003;62(2):232-6. Not eligible target population. [pmid: 12893325].
1015 Dehni N, McNamara DA, Schlegel RD, et al. Clinical effects of preoperative radiation therapy on anorectal function after proctectomy and colonic J-pouch-anal anastomosis. Dis Colon Rectum. Dec. 2002;45(12):1635-40. Case-series. [pmid: 12473887].
1016 Dehni N, Schlegel D, Tiret E, et al. Effects of aging on the functional outcome of coloanal anastomosis with colonic J-pouch. Am J Surg. Mar. 1998;175(3):209-12. Case-series. [pmid: 9560121].
1017 Deindl FM, Vodusek DB, Hesse U, et al. Pelvic floor activity patterns: comparison of nulliparous continent and parous urinary stress incontinent women. A kinesiological EMG study. Br J Urol. Apr. 1994;73(4):413-7. Case-series. [pmid: 8199830].
1018 Del Carro U, Riva D, Comi GC, et al. Neurophysiological evaluation in detrusor instability. Neurourol Urodyn. 1993;12(5):455-62. Not eligible outcomes. [pmid: 8252049].
1019 Del Priore G, Taylor SY, Esdaile BA, et al. Urinary incontinence in gynecological oncology patients. Int J Gynecol Cancer. Sep–Oct. 2005;15(5):911-4. Case control < 100 patients. [pmid: 16174244].
1020 Del Ser T, Hachinski V, Merskey H, et al. Clinical and pathologic features of two groups of patients with dementia with Lewy bodies: effect of coexisting Alzheimer-type lesion load. Alzheimer Dis Assoc Disord. Jan–Mar. 2001;15(1):31-44. Not eligible target population. [pmid: 11236823].
1021 DeLancey JO. Structural support of the urethra as it relates to stress urinary incontinence: the hammock hypothesis. Am J Obstet Gynecol. Jun. 1994;170(6):1713-20. discussion 20–3. Not eligible target population. [pmid: 8203431].
1022 Delancey JO. Fascial and muscular abnormalities in women with urethral hypermobility and anterior vaginal wall prolapse. Am J Obstet Gynecol. Jul. 2002;187(1):93-8. Not eligible outcomes. [pmid: 12114894].
1023 DeLancey JO, Morley GW. Total colpocleisis for vaginal eversion. Am J Obstet Gynecol. Jun. 1997;176(6):1228-32. discussion 32–5. Case-series. [pmid: 9215178].
1024 DeLancey JO, Nygaard I. Exercise-associated urinary incontinence. Jama. Jan 23–30. 1991;265(4):514. Case-reports. [pmid: 1985240].
1025 Delechenaut P, Leroi AM, Weber J, et al. Relationship between clinical symptoms of anal incontinence and the results of anorectal manometry. Dis Colon Rectum. Sep. 1992;35(9):847-9. Not eligible outcomes. [pmid: 1511644].
1026 Delemarre JB, Gooszen HG, Kruyt RH, et al. The effect of posterior rectopexy on fecal continence. A prospective study. Dis Colon Rectum. Apr. 1991;34(4):311-6. Case-series. [pmid: 2007348].
1027 D'Elia G, Pahernik S, Fisch M, et al. Mainz Pouch II technique: 10 years' experience. BJU Int. May. 2004;93(7):1037-42. Case-series. [pmid: 15142160].
1028 Delmas V. Anatomical risks of transobturator suburethral tape in the treatment of female stress urinary incontinence. Eur Urol. Nov. 2005;48(5):793-8. Not eligible target population. [pmid: 16055259].
1029 Delodovici ML, Fowler CJ. Clinical value of the pudendal somatosensory evoked potential. Electroencephalogr Clin Neurophysiol. Nov. 1995;96(6):509-15. Not eligible target population. [pmid: 7489672].
1030 Delorme E, Droupy S, de Tayrac R, et al. Transobturator tape (Uratape): a new minimally-invasive procedure to treat female urinary incontinence. Eur Urol. Feb. 2004;45(2):203-7. Case-series. [pmid: 14734007].
1031 Del-Ser T, Munoz DG, Hachinski V. Temporal pattern of cognitive decline and incontinence is different in Alzheimer's disease and diffuse Lewy body disease. Neurology. Mar. 1996;46(3):682-6. Case-series. [pmid: 8618667].
1032 Demaria F, Porcher R, Ismael SS, et al. Using intercostal muscle EMG to quantify maternal expulsive efforts during vaginal delivery: a pilot study. Neurourol Urodyn. 2004;23(7):675-8. discussion 9. Not eligible outcomes. [pmid: 15382195].
1033 Demirci F, Kuyumcuoglu U, Kekovali M, et al. Perineal ultrasonography in postoperative assessment of two different surgical procedures for stress urinary incontinence. Int Urol Nephrol. 1995;27(3):279-87. Case-series. [pmid: 7591591].
1034 Demirci F, Kuyumcuoglu U, Uludogan M, et al. Evaluation of urethrovesical junction mobility by perineal ultrasonography in stress urinary incontinence. J Pak Med Assoc. Jan. 1996;46(1):2-5. Not eligible outcomes. [pmid: 8830164].
1035 Demirci F, Ozdemir I, Somunkiran A, et al. Abdominal sacrohysteropexy in young women with uterovaginal prolapse: results of 20 cases. J Reprod Med. Jul. 2006;51(7):539-43. Case-series. [pmid: 16913544].
1036 Demirci F, Ozden S, Alpay Z, et al. The effects of abdominal hysterectomy on bladder neck and urinary incontinence. Aust N Z J Obstet Gynaecol. May. 1999;39(2):239-42. Not eligible outcomes. [pmid: 10755788].
1037 Demirci F, Ozden S, Alpay Z, et al. The effects of vaginal delivery and cesarean section on bladder neck mobility and stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):129-33. Question 2. [pmid: 11374511].
1038 Demirci F, Yucel O, Eren S, et al. Long-term results of Burch colposuspension. Gynecol Obstet Invest. 2001;51(4):243-7. Case-series. [pmid: 11408735].
1039 Denays R, Tondeur M, Noel P, et al. Bilateral cerebral mediofrontal hypoactivity in Tc-99m HMPAO SPECT imaging. Clin Nucl Med. Oct. 1994;19(10):873-6. Not eligible outcomes. [pmid: 7805320].
1040 Denberg TD, Flanigan RC, Kim FJ, et al. Self-reported volume of radical prostatectomies among urologists in the USA. BJU Int. Feb. 2007;99(2):339-43. Not eligible outcomes. [pmid: 17155974].
1041 Denewer A. A low-pressure rectosigmoid pouch created by side-to-side anastomosis with a stapling technique and sigmoid colon intussusception as an antireflux procedure. Br J Urol. Jun. 1998;81(6):856-61. Case-series. [pmid: 9666771].
1042 Deng J, Hall-Craggs MA, Craggs MD, et al. Three-dimensional MRI of the male urethrae with implanted artificial sphincters: initial results. Br J Radiol. Jun. 2006;79(942):455-63. Not eligible outcomes. [pmid: 16714745].
1043 Deniz N, Perk H, Serel T, et al. Urethral coitus and urinary incontinence in a case of Mayer-Rokitansky syndrome: an alternative surgical procedure. Eur J Obstet Gynecol Reprod Biol. Jun 10. 2002;103(1):95-6. Case Reports. [pmid: 12039475].
1044 Dennis PJ, Rohner TJ Jr, Hu TW, et al. Simple urodynamic evaluation of incontinent elderly female nursing home patients. A descriptive analysis. Urology. Feb. 1991;37(2):173-9. Not eligible target population. [pmid: 1992590].
1045 Desai MM, Zhang P, Hennessy CH. Surveillance for morbidity and mortality among older adults—United States, 1995-1996. MMWR CDC Surveill Summ. Dec 17. 1999;48(8):7-25. Review. [pmid: 10634269].
1046 Desautel MG, Kapoor R, Badlani GH. Sphincteric incontinence: the primary cause of post-prostatectomy incontinence in patients with prostate cancer. Neurourol Urodyn. 1997;16(3):153-60. Case-series. [pmid: 9136137].
1047 deSouza NM, Daniels OJ, Williams AD, et al. Female urinary genuine stress incontinence: anatomic considerations at MR imaging of the paravaginal fascia and urethra initial observations. Radiology. Nov. 2002;225(2):433-9. Not eligible outcomes. [pmid: 12409577].
1048 deSouza NM, Puni R, Kmiot WA, et al. MRI of the anal sphincter. J Comput Assist Tomogr. Sep–Oct. 1995;19(5):745-51. Question 4. [pmid: 7560320].
1049 deSouza NM, Puni R, Zbar A, et al. MR imaging of the anal sphincter in multiparous women using an endoanal coil: correlation with in vitro anatomy and appearances in fecal incontinence. AJR Am J Roentgenol. Dec. 1996;167(6):1465-71. Question 4. [pmid: 8956578].
1050 deSouza NM, Williams AD, Wilson HJ, et al. Fecal incontinence in scleroderma: assessment of the anal sphincter with thin-section endoanal MR imaging. Radiology. Aug. 1998;208(2):529-35. Not eligible outcomes. [pmid: 9680588].
1051 Deutekom M, Dobben AC, Dijkgraaf MG, et al. Costs of outpatients with fecal incontinence. Scand J Gastroenterol. May. 2005;40(5):552-8. Not eligible outcomes. [pmid: 16036507].
1052 Deutekom M, Terra MP, Dijkgraaf MG, et al. Patients' perception of tests in the assessment of faecal incontinence. Br J Radiol. Feb. 2006;79(938):94-100. Not eligible outcomes. [pmid: 16489189].
1053 Deutekom M, Terra MP, Dobben AC, et al. Impact of faecal incontinence severity on health domains. Colorectal Dis. May. 2005;7(3):263-9. Case-series. [pmid: 15859965].
1054 Deutekom M, Terra MP, Dobben AC, et al. Selecting an outcome measure for evaluating treatment in fecal incontinence. Dis Colon Rectum. Dec. 2005;48(12):2294-301. Not eligible target population. [pmid: 16400514].
1055 Deval B, Ferchaux J, Berry R, et al. Objective and subjective cure rates after trans-obturator tape (OBTAPE) treatment of female urinary incontinence. Eur Urol. Feb. 2006;49(2):373-7. Not eligible target population. [pmid: 16413657].
1056 Deval B, Levardon M, Samain E, et al. A French multicenter clinical trial of SPARC for stress urinary incontinence. Eur Urol. Aug. 2003;44(2):254-8. discussion 8–9. Not eligible target population. [pmid: 12875946].
1057 Devarajan R, Bishop MC, Sands KA. Hepatic abscess: a tertiary complication of Mitrofanoff continent urinary diversion. Br J Urol. Jan. 1997;79(1):137-8. Case Reports. [pmid: 9043519].
1058 Devesa JM, Madrid JM, Gallego BR, et al. Bilateral gluteoplasty for fecal incontinence. Dis Colon Rectum. Aug. 1997;40(8):883-8. Case-series. [pmid: 9269802].
1059 Devesa JM, Rey A, Hervas PL, et al. Artificial anal sphincter: complications and functional results of a large personal series. Dis Colon Rectum. Sep. 2002;45(9):1154-63. Not eligible target population. [pmid: 12352229].
1060 Devesa JM, Vicente E, Enriquez JM, et al. Total fecal incontinence—a new method of gluteus maximus transposition: preliminary results and report of previous experience with similar procedures. Dis Colon Rectum. Apr. 1992;35(4):339-49. Case-series. [pmid: 1582355].
1061 Devreese A, Staes F, De Weerdt W, et al. Clinical evaluation of pelvic floor muscle function in continent and incontinent women. Neurourol Urodyn. 2004;23(3):190-7. Not eligible outcomes. [pmid: 15098213].
1062 deVries CR, Anderson RU. Endoscopic urethroplasty: an improved technique. J Urol. Jun. 1990;143(6):1225-6. Case Reports. [pmid: 2342187].
1063 Devroey D, Van Casteren V, Buntinx F. Registration of stroke through the Belgian sentinel network and factors influencing stroke mortality. Cerebrovasc Dis. 2003;16(3):272-9. Not eligible outcomes. [pmid: 12865616].
1064 Dhaenens G, Emblem R, Ganes T. Fibre density in idiopathic ano-rectal incontinence. Electromyogr Clin Neurophysiol. Aug–Sep. 1995;35(5):285-90. Not eligible outcomes. [pmid: 7498073].
1065 D'Hoore A, Cadoni R, Penninckx F. Long-term outcome of laparoscopic ventral rectopexy for total rectal prolapse. Br J Surg. Nov. 2004;91(11):1500-5. Case-series. [pmid: 15499644].
1066 Di Carlo A, Lamassa M, Baldereschi M, et al. Sex differences in the clinical presentation, resource use, and 3-month outcome of acute stroke in Europe: data from a multicenter multinational hospital-based registry. Stroke. May. 2003;34(5):1114-9. Not eligible level of evidence. [pmid: 12690218].
1067 Di Carlo A, Lamassa M, Pracucci G, et al. Stroke in the very old: clinical presentation and determinants of 3-month functional outcome: A European perspective. European BIOMED Study of Stroke Care Group. Stroke. Nov. 1999;30(11):2313-9. Not eligible level of evidence. [pmid: 10548664].
1068 Di Gangi Herms AM, Pinggera GM, De Jonge P, et al. Assessing health care needs and clinical outcome with urological case complexity: a study using INTERMED. Psychosomatics. May–Jun. 2003;44(3):196-203. Not eligible outcomes. [pmid: 12724500].
1069 Di Gangi Herms AM, Veit R, Reisenauer C, et al. Functional imaging of stress urinary incontinence. Neuroimage. Jan 1. 2006;29(1):267-75. Case-series. [pmid: 16150613].
1070 Di Giorgio A, Biacchi D, Sibio S, et al. Abdominal rectopexy for complete rectal prolapse: preliminary results of a new technique. Int J Colorectal Dis. Mar. 2005;20(2):180-9. Case-series. [pmid: 15688100].
1071 Diana M, Zoppe C, Mastrangeli B. Treatment of vaginal vault prolapse with abdominal sacral colpopexy using prolene mesh. Am J Surg. Feb. 2000;179(2):126-8. Case-series. [pmid: 10773148].
1072 Dichgans M, Mayer M, Uttner I, et al. The phenotypic spectrum of CADASIL: clinical findings in 102 cases. Ann Neurol. Nov. 1998;44(5):731-9. Not eligible level of evidence. [pmid: 9818928].
1073 Dietz HP, Clarke B, Vancaillie TG. Vaginal childbirth and bladder neck mobility. Aust N Z J Obstet Gynaecol. Nov. 2002;42(5):522-5. Not eligible level of evidence. [pmid: 12495100].
1074 Dietz HP, Eldridge A, Grace M, et al. Does pregnancy affect pelvic organ mobility?. Aust N Z J Obstet Gynaecol. Dec. 2004;44(6):517-20. Not eligible outcomes. [pmid: 15598288].
1075 Dietz HP, Eldridge A, Grace M, et al. Pelvic organ descent in young nulligravid women. Am J Obstet Gynecol. Jul. 2004;191(1):95-9. Not eligible outcomes. [pmid: 15295348].
1076 Dietz HP, Hansell NK, Grace ME, et al. Bladder neck mobility is a heritable trait. Bjog. Mar. 2005;112(3):334-9. Not eligible exposure. [pmid: 15713150].
1077 Dietz HP, Haylen BT. Symptoms of voiding dysfunction: what do they really mean?. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):52-5. discussion 5. Not eligible outcomes. [pmid: 15647963].
1078 Dietz HP, Jarvis SK, Vancaillie TG. The assessment of levator muscle strength: a validation of three ultrasound techniques. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(3):156-9. discussion 9. Not eligible outcomes. [pmid: 12140708].
1079 Dietz HP, Lanzarone V. Levator trauma after vaginal delivery. Obstet Gynecol. Oct. 2005;106(4):707-12. Case-series. [pmid: 16199625].
1080 Dietz HP, Mouritsen L, Ellis G, et al. Does the tension-free vaginal tape stay where you put it?. Am J Obstet Gynecol. Apr. 2003;188(4):950-3. Not eligible outcomes. [pmid: 12712092].
1081 Dietz HP, Mouritsen L, Ellis G, et al. How important is TVT location?. Acta Obstet Gynecol Scand. Oct. 2004;83(10):904-8. Not eligible outcomes. [pmid: 15453883].
1082 Dietz HP, Steensma AB. The prevalence of major abnormalities of the levator ani in urogynaecological patients. Bjog. Feb. 2006;113(2):225-30. Not eligible outcomes. [pmid: 16412002].
1083 Dietz HP, Wilson PD. The influence of bladder volume on the position and mobility of the urethrovesical junction. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):3-6. Not eligible target population. [pmid: 10207759].
1084 Dietz HP, Wilson PD. Colposuspension success and failure: a long-term objective follow-up study. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2000;11(6):346-51. Case-series. [pmid: 11147742].
1085 Dietz HP, Wilson PD. Laparoscopic colposuspension versus urethropexy: a case-control series. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):15-8. discussion 8. Not eligible target population. [pmid: 15647961].
1086 Dietz HP, Wilson PD, Clarke B. The use of perineal ultrasound to quantify levator activity and teach pelvic floor muscle exercises. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(3):166-8. discussion 8–9. Case-series. [pmid: 11451004].
1087 Digesu GA, Chaliha C, Salvatore S, et al. The relationship of vaginal prolapse severity to symptoms and quality of life. Bjog. Jul. 2005;112(7):971-6. Not eligible outcomes. [pmid: 15958002].
1088 Digesu GA, Khullar V, Cardozo L, et al. Preoperative pressure-flow studies: useful variables to predict the outcome of continence surgery. BJU Int. Dec. 2004;94(9):1296-9. Not eligible outcomes. [pmid: 15610109].
1089 Diggs C, Meyer WA, Langenberg P, et al. Assessing urgency in interstitial cystitis/painful bladder syndrome. Urology. Feb. 2007;69(2):210-4. Not eligible outcomes. [pmid: 17275075]. [pmcid: 1855150].
1090 Dijkema HE, Weil EH, Mijs PT, et al. Neuromodulation of sacral nerves for incontinence and voiding dysfunctions. Clinical results and complications. Eur Urol. 1993;24(1):72-6. Case-series.
1091 Dikranian AH, Chang JH, Rhee EY, et al. The male perineal sling: comparison of sling materials. J Urol. Aug. 2004;172(2):608-10. Case-series. [pmid: 15247743].
1092 Diller LM. Post-TURP incontinence. Urol Nurs. Feb. 2000;20(1):54. Case report. [pmid: 11998042].
1093 Dimachkie MM, Ohanian S, Groves MD, et al. Peripheral nerve injury after brief lithotomy for transurethral collagen injection. Urology. Oct 1. 2000;56(4):669. Case-reports.
1094 DiMarco DS, Elliott DS. Tandem cuff artificial urinary sphincter as a salvage procedure following failed primary sphincter placement for the treatment of post-prostatectomy incontinence. J Urol. Oct. 2003;170(4 Pt 1):1252-4. Case-series. [pmid: 14501735].
1095 Dimitri M. TURP with the new superpulsed radiofrequency energy: More than a gold standard. Eur Urol. Oct. 1999;36(4):331-4. Not eligible outcomes. [pmid: 10473994].
1096 Ding YY, Jayaratnam FJ. Urinary incontinence in the hospitalised elderly—a largely reversible disorder. Singapore Med J. Apr. 1994;35(2):167-70. Not eligible target population. [pmid: 7939813].
1097 Ding YY, Sahadevan S, Pang WS, et al. Clinical utility of a portable ultrasound scanner in the measurement of residual urine volume. Singapore Med J. Aug. 1996;37(4):365-8. Not eligible outcomes. [pmid: 8993133].
1098 Dingwall L, McLafferty E. Do nurses promote urinary continence in hospitalized older people?: An exploratory study. J Clin Nurs. Oct. 2006;15(10):1276-86. Not eligible target population. [pmid: 16968432].
1099 Diokno A, Lee P, Zorn BH, et al. Factors associated with clinical assessment of overactive bladder and selection of treatment. Clin Ther. Sep. 2001;23(9):1542-51. Not eligible target population. [pmid: 11589266].
1100 Diokno A, Sand P, Labasky R, et al. Long-term safety of extended-release oxybutynin chloride in a community-dwelling population of participants with overactive bladder: a one-year study. Int Urol Nephrol. 2002;34(1):43-9. Not eligible outcomes. [pmid: 12549638].
1101 Diokno A, Yuhico M Jr. Preference, compliance and initial outcome of therapeutic options chosen by female patients with urinary incontinence. J Urol. Nov. 1995;154(5):1727-30. discussion 31. Not eligible outcomes. [pmid: 7563333].
1102 Diokno AC. Epidemiology and psychosocial aspects of incontinence. Urol Clin North Am. Aug. 1995;22(3):481-5. Comment. [pmid: 7645150].
1103 Diokno AC, Appell RA, Sand PK, et al. Prospective, randomized, double-blind study of the efficacy and tolerability of the extended-release formulations of oxybutynin and tolterodine for overactive bladder: results of the OPERA trial. Mayo Clin Proc. Jun. 2003;78(6):687-95. Not eligible exposure. [pmid: 12934777].
1104 Diokno AC, Brown MB, Herzog AR. Sexual function in the elderly. Arch Intern Med. Jan. 1990;150(1):197-200. Not eligible outcomes. [pmid: 2297288].
1105 Diokno AC, Burgio K, Fultz H, et al. Prevalence and outcomes of continence surgery in community dwelling women. J Urol. Aug. 2003;170(2 Pt 1):507-11. Not eligible level of evidence. [pmid: 12853810].
1106 Diokno AC, Burgio K, Fultz NH, et al. Medical and self-care practices reported by women with urinary incontinence. Am J Manag Care. Feb. 2004;10(2 Pt 1):69-78. Not eligible level of evidence. [pmid: 15011807].
1107 Dippel DW, Habbema JD. Probabilistic diagnosis of normal pressure hydrocephalus and other treatable cerebral lesions in dementia. J Neurol Sci. Nov. 1993;119(2):123-33. Not eligible outcomes. [pmid: 8277325].
1108 Discolo CM, Akst LM, Schlossberg L, et al. Anterior cranial fossa glioblastoma with sleep apnea as the initial manifestation. Am J Otolaryngol. Sep–Oct. 2005;26(5):327-9. Case-reports. [pmid: 16137531].
1109 Diseth TH. Dissociation following traumatic medical treatment procedures in childhood: a longitudinal follow-up. Dev Psychopathol. Winter. 2006;18(1):233-51. Not eligible target population. [pmid: 16478561].
1110 Diseth TH, Bjordal R, Schultz A, et al. Somatic function, mental health and psychosocial functioning in 22 adolescents with bladder exstrophy and epispadias. J Urol. May. 1998;159(5):1684-9. discussion 9–90. Not eligible target population. [pmid: 9554394].
1111 Diseth TH, Bjornland K, Novik TS, et al. Bowel function, mental health, and psychosocial function in adolescents with Hirschsprung's disease. Arch Dis Child. Feb. 1997;76(2):100-6. Not eligible target population. [pmid: 9068296]. [pmcid: 1717056].
1112 Diseth TH, Egeland T, Emblem R. Effects of anal invasive treatment and incontinence on mental health and psychosocial functioning of adolescents with Hirschsprung's disease and low anorectal anomalies. J Pediatr Surg. Mar. 1998;33(3):468-75. Not eligible target population. [pmid: 9537559].
1113 Diseth TH, Emblem R. Somatic function, mental health, and psychosocial adjustment of adolescents with anorectal anomalies. J Pediatr Surg. May. 1996;31(5):638-43. Not eligible target population. [pmid: 8861471].
1114 Dixon GR, Friedman JA, Luetmer PH, et al. Use of cerebrospinal fluid flow rates measured by phase-contrast MR to predict outcome of ventriculoperitoneal shunting for idiopathic normal-pressure hydrocephalus. Mayo Clin Proc. Jun. 2002;77(6):509-14. Case-series. [pmid: 12059119].
1115 Dixon PJ, Christmas TJ, Chapple CR. Stress incontinence due to pelvic floor muscle involvement in limb-girdle muscular dystrophy. Br J Urol. Jun. 1990;65(6):653-4. Case Reports. [pmid: 2372681].
1116 Djaladat H, Mehrsai A, Saraji A, et al. Suprapubic prostatectomy with a novel catheter. J Urol. Jun. 2006;175(6):2083-6. Not eligible exposure. [pmid: 16697808].
1117 Dmochowski R. Urinary frequency: event measure, outcome significance?. Curr Urol Rep. Mar. 2005;6(2):87-8. No associative hypothesis tested. [pmid: 15717963].
1118 Dmochowski RR. Management of postoperative overactive bladder complications. Geriatrics. May. 2002;57(Suppl 1):18-23. Review. [pmid: 12040599].
1119 Dmochowski RR, Avon M, Ross J, et al. Transvaginal radio frequency treatment of the endopelvic fascia: a prospective evaluation for the treatment of genuine stress urinary incontinence. J Urol. Mar. 2003;169(3):1028-32. Not eligible target population. [pmid: 12576838].
1120 Dmochowski RR, Davila GW, Zinner NR, et al. Efficacy and safety of transdermal oxybutynin in patients with urge and mixed urinary incontinence. J Urol. Aug. 2002;168(2):580-6. Not eligible exposure. [pmid: 12131314].
1121 Dmochowski RR, Miklos JR, Norton PA, et al. Duloxetine versus placebo for the treatment of North American women with stress urinary incontinence. J Urol. Oct. 2003;170(4 Pt 1):1259-63. Not eligible exposure. [pmid: 14501737].
1122 Dmochowski RR, Nitti V, Staskin D, et al. Transdermal oxybutynin in the treatment of adults with overactive bladder: combined results of two randomized clinical trials. World J Urol. Sep. 2005;23(4):263-70. Not eligible exposure. [pmid: 16151816].
1123 Dmochowski RR, Sand PK, Zinner NR, et al. Comparative efficacy and safety of transdermal oxybutynin and oral tolterodine versus placebo in previously treated patients with urge and mixed urinary incontinence. Urology. Aug. 2003;62(2):237-42. Not eligible exposure. [pmid: 12893326].
1124 Dmochowski RR, Zimmern PE, Ganabathi K, et al. Role of the four-corner bladder neck suspension to correct stress incontinence with a mild to moderate cystocele. Urology. Jan. 1997;49(1):35-40. Not eligible target population.
1125 Doan T, Patterson R, Greenberger PA. Cough variant asthma: usefulness of a diagnostic-therapeutic trial with prednisone. Ann Allergy. Dec. 1992;69(6):505-9. Not eligible target population. [pmid: 1471782].
1126 Dobben AC, Terra MP, Berghmans B, et al. Functional changes after physiotherapy in fecal incontinence. Int J Colorectal Dis. Sep. 2006;21(6):515-21. Case-series. [pmid: 16244864].
1127 Dobben AC, Terra MP, Slors JF, et al. External anal sphincter defects in patients with fecal incontinence: comparison of endoanal MR imaging and endoanal US. Radiology. Feb. 2007;242(2):463-71. Not eligible outcomes. [pmid: 17255418].
1128 Dobben AC, Wiersma TG, Janssen LW, et al. Prospective assessment of interobserver agreement for defecography in fecal incontinence. AJR Am J Roentgenol. Nov. 2005;185(5):1166-72. Not eligible outcomes. [pmid: 16247127].
1129 Docimo SG, Remmenga S, Segne R, et al. Hysterectomy by the transvaginal approach after intestinal bladder augmentation and psoas hitch reimplantation. J Am Coll Surg. May. 1995;180(5):610-2. Case Reports. [pmid: 7749540].
1130 Dodi G, Pietroletti R, Milito G, et al. Bleeding, incontinence, pain and constipation after STARR transanal double stapling rectotomy for obstructed defecation. Tech Coloproctol. Oct. 2003;7(3):148-53. Case-series. [pmid: 14628157].
1131 Dogan AS, Kirchner PT. Hepatobiliary excretion of MAG3. Simulation of a urinary leak. Clin Nucl Med. Sep. 1993;18(9):746-50. Case Reports. [pmid: 8403715].
1132 Dogra PN, Ansari MS. Spinning top urethra and lower urinary tract dysfunction in a young female. ScientificWorldJournal. Jun 7. 2004;4(Suppl 1):108-10. Case-reports. [pmid: 15349536].
1133 Dogra PN, Prashad R, Goel R, et al. Paradoxical incontinence caused by “invisible dysplastic” kidneys: role of laparoscopy. Int Urol Nephrol. 2002;34(1):17-8. Case Reports. [pmid: 12549632].
1134 Doherty W. TENA flex: a new concept in disposable incontinence pads. Br J Nurs 2003 Mar 13–26; 12(5):327–8, 30. Comment
1135 Dolan LM, Hosker GL, Mallett VT, et al. Stress incontinence and pelvic floor neurophysiology 15 years after the first delivery. Bjog. Dec. 2003;110(12):1107-14. Not eligible target population. [pmid: 14664882].
1136 Dolman M, Chase J. Comparison between the Health Belief Model and Subjective Expected Utility Theory: predicting incontinence prevention behaviour in post-partum women. J Eval Clin Pract. Aug. 1996;2(3):217-22. Not eligible outcomes. [pmid: 9238593].
1137 Donaldson MM, Thompson JR, Matthews RJ, et al. The natural history of overactive bladder and stress urinary incontinence in older women in the community: a 3-year prospective cohort study. Neurourol Urodyn. 2006;25(7):709-16. Not eligible outcomes. [pmid: 16998862].
1138 Donato DM, Waller-Smith S. The vaginal-psoas suspension repair of uterovaginal prolapse. J Am Coll Surg. Jul. 2002;195(1):51-4. Case-series. [pmid: 12113545].
1139 Dong D, Xu Z, Shi B, et al. Urodynamic study in the neurogenic bladder dysfunction caused by intervertebral disk hernia. Neurourol Urodyn. 2006;25(5):446-50. Case-series. [pmid: 16847921].
1140 Doniec JM, Schniewind B, Kovacs G, et al. Multimodal therapy of anal cancer added by new endosonographic-guided brachytherapy. Surg Endosc. Apr. 2006;20(4):673-8. Case-series. [pmid: 16432657].
1141 Donnellan SM, Duncan HJ, MacGregor RJ, et al. Prospective assessment of incontinence after radical retropubic prostatectomy: objective and subjective analysis. Urology. Feb. 1997;49(2):225-30. Not eligible outcomes. [pmid: 9037284].
1142 Donnelly MJ, Powell-Morgan S, Olsen AL, et al. Vaginal pessaries for the management of stress and mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):302-7. Not eligible outcomes. [pmid: 15300365].
1143 Donnelly V, O'Connell PR, O'Herlihy C. The influence of oestrogen replacement on faecal incontinence in postmenopausal women. Br J Obstet Gynaecol. Mar. 1997;104(3):311-5. Not eligible target population. [pmid: 9091007].
1144 Dooneief G, Marlink R, Bell K, et al. Neurologic consequences of HTLV-II infection in injection-drug users. Neurology. Jun. 1996;46(6):1556-60. Not eligible exposure. [pmid: 8649548].
1145 Doran CM, Chiarelli P, Cockburn J. Economic costs of urinary incontinence in community-dwelling Australian women. Med J Aust. May 7. 2001;174(9):456-8. Secondary data analysis. [pmid: 11386591].
1146 Dorey G, Feneley RC, Speakman MJ, et al. Pelvic floor muscle exercises and manometric biofeedback for erectile dysfunction and postmicturition dribble: three case studies. J Wound Ostomy Continence Nurs. Jan. 2003;30(1):44-51. discussion -2. Case-reports. [pmid: 12529593].
1147 Dornan PR. Incontinence—an aggressive approach to treatment: a case series. J Sci Med Sport. Dec. 2005;8(4):458-62. Case-series. [pmid: 16602175].
1148 Douard R, Frileux P, Brunel M, et al. Functional results after the Orr-Loygue transabdominal rectopexy for complete rectal prolapse. Dis Colon Rectum. Aug. 2003;46(8):1089-96. Case-series. [pmid: 12907904].
1149 Dougherty MC, Dwyer JW, Pendergast JF, et al. Community-based nursing: continence care for older rural women. Nurs Outlook. Sep–Oct. 1998;46(5):233-44. No associative hypothesis tested. [pmid: 9805343].
1150 Dovey S, McNaughton T, Tilyard M, et al. General practitioners' opinions of continence care training. N Z Med J. Sep 13. 1996;109(1029):340-3. Not eligible target population. [pmid: 8862354].
1151 Dowd T, Kolcaba K, Steiner R. Correlations among measures of bladder function and comfort. J Nurs Meas. Spring–Summer. 2002;10(1):27-38. Not eligible outcomes. [pmid: 12048966].
1152 Dowd T, Kolcaba K, Steiner R. The addition of coaching to cognitive strategies: interventions for persons with compromised urinary bladder syndrome. J Wound Ostomy Continence Nurs. Mar. 2003;30(2):90-9. Not eligible outcomes. [pmid: 12658237].
1153 Dowd TT, Campbell JM. Urinary incontinence in an acute care setting. Urol Nurs. Sep. 1995;15(3):82-5. Not eligible target population. [pmid: 7481891].
1154 Dowell CJ, Bryant CM, Moore KH, et al. Calculating the direct costs of urinary incontinence: a new test instrument. BJU Int. Apr. 1999;83(6):596-606. Not eligible outcomes. [pmid: 10233564].
1155 Downs TM, Sadetsky N, Pasta DJ, et al. Health related quality of life patterns in patients treated with interstitial prostate brachytherapy for localized prostate cancer—data from CaPSURE. J Urol. Nov. 2003;170(5):1822-7. Case Series. [pmid: 14532784].
1156 Dowse J, Fordham S, Mackender J. Back to basics continence. Nurs Times Nurs Homes 1999 Nov–Dec; 1(4):23–5, 7. Comment
1157 Dowse J, Mackender J. Back to basics: continence. Nurs Times. Jul 27. 2000;96(30 Suppl):7-9. Comment. [pmid: 11963433].
1158 Drachman DA, O'Donnell BF, Lew RA, et al. The prognosis in Alzheimer's disease. ‘How far’ rather than ‘how fast’ best predicts the course. Arch Neurol. Aug. 1990;47(8):851-6. Case-series. [pmid: 2375690].
1159 Drago JR, Badalament RA, Nesbitt JA. Radical prostatectomy 1972-1987 single institutional experience: comparison of standard radical prostatectomy and nerve-sparing technique. Urology. May. 1990;35(5):377-80. Case-series. [pmid: 1692432].
1160 Drago JR, Badalament RA, Nesbitt JA, et al. Radical nerve-sparing prostatectomy with epidural anaesthesia in 100 patients. Br J Urol. May. 1990;65(5):517-9. Case-series. [pmid: 2191741].
1161 Drent ML, van der Veen EA. Lipase inhibition: a novel concept in the treatment of obesity. Int J Obes Relat Metab Disord. Apr. 1993;17(4):241-4. Not eligible outcomes. [pmid: 8387973].
1162 Drutz HP, Appell RA, Gleason D, et al. Clinical efficacy and safety of tolterodine compared to oxybutynin and placebo in patients with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):283-9. Not eligible exposure. [pmid: 10543335].
1163 Dubbs J. Addressing an urgent need. Rehab Manag 2006 Aug–Sep; 19(7):32–4, 6–7. Comment
1164 DuBeau C. Urinary incontinence: taking action against this ‘silent epidemic’. Interview by Marc E. Weksler. Geriatrics. Apr. 1996;51(4):47-51. Interview.
1165 DuBeau CE. The continuum of urinary incontinence in an aging population. Geriatrics. May. 2002;57(Suppl 1):12-7. Comment. [pmid: 12040598].
1166 DuBeau CE, Khullar V, Versi E. “Unblinding” in randomized controlled drug trials for urinary incontinence: Implications for assessing outcomes when adverse effects are evident. Neurourol Urodyn. 2005;24(1):13-20. Not eligible exposure. [pmid: 15570576].
1167 DuBeau CE, Kiely DK, Resnick NM. Quality of life impact of urge incontinence in older persons: a new measure and conceptual structure. J Am Geriatr Soc. Aug. 1999;47(8):989-94. Not eligible outcomes. [pmid: 10443861].
1168 Dubeau CE, Simon SE, Morris JN. The effect of urinary incontinence on quality of life in older nursing home residents. J Am Geriatr Soc. Sep. 2006;54(9):1325-33. Not eligible outcomes. [pmid: 16970638].
1169 Dubernard G, Rouzier R, Haddad B, et al. Correction of uterine prolapse by the vaginal route using the uterosacral ligaments: Shirodkar procedure. Eur J Obstet Gynecol Reprod Biol. Aug 15. 2003;109(2):214-8. Case-series. [pmid: 12860345].
1170 Duchesne GM, Dowling C, Frydenberg M, et al. Outcome, morbidity, and prognostic factors in post-prostatectomy radiotherapy: an Australian multicenter study. Urology. Jan. 2003;61(1):179-83. Not eligible level of evidence. [pmid: 12559292].
1171 Duckett JR, Tamilselvi A. Effect of tension-free vaginal tape in women with a urodynamic diagnosis of idiopathic detrusor overactivity and stress incontinence. Bjog. Jan. 2006;113(1):30-3. Not eligible outcomes. [pmid: 16398768].
1172 Duckett JR, Tamilselvi A, Jain S. Foley catheter tamponade of bleeding in the cave of Retzius after a Tension Free Vaginal Tape procedure. J Obstet Gynaecol. Jan. 2005;25(1):80-1. Case- Reports. [pmid: 16147711].
1173 Duckett JR, Vella M, Kavalakuntla G, et al. Tolerability and efficacy of duloxetine in a nontrial situation. BJOG. May. 2007;114(5):543-7. Not eligible outcomes. [pmid: 17355360].
1174 Dudderidge TJ, Haynes SV, Davies AJ, et al. Vesicocervical fistula: rare complication of cesarean section demonstrated by magnetic resonance imaging. Urology. Jan. 2005;65(1):174. Case Reports.
1175 Duel BP, Gonzalez R. The button cecostomy for management of fecal incontinence. Pediatr Surg Int. 1999;15(8):559-61. Case-series. [pmid: 10631733].
1176 Duffau H, Capelle L. Incontinence after brain glioma surgery: new insights into the cortical control of micturition and continence. Case report. J Neurosurg. Jan. 2005;102(1):148-51. Case Reports. [pmid: 15658106].
1177 Duffy LM. Continence management for the frail elderly and cognitively impaired. Urol Nurs. Jun. 1992;12(2):66-8. Comment. [pmid: 1609312].
1178 Dugan E, Cohen SJ, Bland DR, et al. The association of depressive symptoms and urinary incontinence among older adults. J Am Geriatr Soc. Apr. 2000;48(4):413-6. Not eligible outcomes. [pmid: 10798468].
1179 Duggan PM, Wilson PD, Norton P, et al. Utilization of preoperative urodynamic investigations by gynecologists who frequently operate for female urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):282-7. discussion 6–7. Not eligible outcomes. [pmid: 14530842].
1180 Duldulao KE, Diokno AC, Mitchell B. Value of urinary cytology in women presenting with urge incontinence and/or irritative voiding symptoms. J Urol. Jan. 1997;157(1):113-6. Not eligible outcomes. [pmid: 8976229].
1181 Dumoulin C, Seaborne DE, Quirion-DeGirardi C, et al. Pelvic-floor rehabilitation, Part 2: Pelvic-floor reeducation with interferential currents and exercise in the treatment of genuine stress incontinence in postpartum women—a cohort study. Phys Ther. Dec. 1995;75(12):1075-81. Case-reports. [pmid: 7501710].
1182 Dumoulin C, Seaborne DE, Quirion-DeGirardi C, et al. Pelvic-floor rehabilitation, Part 1: Comparison of two surface electrode placements during stimulation of the pelvic-floor musculature in women who are continent using bipolar interferential currents. Phys Ther. Dec. 1995;75(12):1067-74. Not eligible outcomes. [pmid: 7501709].
1183 Dumville JC, Manca A, Kitchener HC, et al. Cost-effectiveness analysis of open colposuspension versus laparoscopic colposuspension in the treatment of urodynamic stress incontinence. Bjog. Sep. 2006;113(9):1014-22. Not eligible outcomes. [pmid: 16956333].
1184 Dunn JS Jr, Gruber D, Broberg J, et al. Urogynecology practice patterns among Air Force obstetricians and gynecologists: survey results. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2006;17(6):598-603. Not eligible target population. [pmid: 16820999].
1185 Dunn KL, Galka ML. A comparison of the effectiveness of Therevac SB and bisacodyl suppositories in SCI patients' bowel programs. Rehabil Nurs. Nov–Dec. 1994;19(6):334-8. Not eligible outcomes. [pmid: 7531868].
1186 Duong TH, Korn AP. A comparison of urinary incontinence among African American, Asian, Hispanic, and white women. Am J Obstet Gynecol. May. 2001;184(6):1083-6. Not eligible target population. [pmid: 11349164].
1187 Durgun V, Perek A, Kapan M, et al. Partial fistulotomy and modified cutting seton procedure in the treatment of high extrasphincteric perianal fistulae. Dig Surg. 2002;19(1):56-8. Case-series. [pmid: 11961357].
1188 Duru S, Ceylan S, Ceylan S. Optic chiasm diastasis in a pituitary tumor. Case illustration. J Neurosurg. Feb. 1999;90(2):363. Case Reports. [pmid: 9950510].
1189 Duso S. Product notebook: a new fecal containment device. A case study describing one use of the Bard FCD fecal containment device. Ostomy Wound Manage. Jun. 1992;38(5):38-41. Case- Reports.
1190 Duthie GS, Bartolo DC. Abdominal rectopexy for rectal prolapse: a comparison of techniques. Br J Surg. Feb. 1992;79(2):107-13. Case-series. [pmid: 1555053].
1191 Dwyer PL, Carey MP, Rosamilia A. Suture injury to the urinary tract in urethral suspension procedures for stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):15-21. Not eligible target population. [pmid: 10207762].
1192 Dwyer PL, Desmedt E. Impaired bladder emptying in women. Aust N Z J Obstet Gynaecol. Feb. 1994;34(1):73-8. Question 1. [pmid: 8053880].
1193 Dwyer PL, Teele JS. Prazosin: a neglected cause of genuine stress incontinence. Obstet Gynecol. Jan. 1992;79(1):117-21. Not eligible target population. [pmid: 1727569].
1194 Dykes EH, Duffy PG, Ransley PG. The use of the Mitrofanoff principle in achieving clean intermittent catheterisation and urinary continence in children. J Pediatr Surg. May. 1991;26(5):535-8. Not eligible target population. [pmid: 2061804].
1195 Eason EL, Feldman P. Contact dermatitis associated with the use of Always sanitary napkins. Cmaj. Apr 15. 1996;154(8):1173-6. Not eligible outcomes. [pmid: 8612252]. [pmcid: 1487684].
1196 Easton BT. Is hormone replacement therapy (estrogen plus progestin) effective for the treatment of urinary incontinence in postmenopausal women?. J Fam Pract. May. 2001;50(5):470. Comment. [pmid: 11350716].
1197 Eastwood S, Kralik D, Koch T. Compromising and containing: self-management strategies used by men and women who live with multiple sclerosis and urinary incontinence. Aust J Holist Nurs. Apr. 2002;9(1):33-43. Not eligible outcomes. [pmid: 12056315].
1198 Eberle CM, Winsemius D, Garibaldi RA. Risk factors and consequences of bacteriuria in non-catheterized nursing home residents. J Gerontol. Nov. 1993;48(6):M266-71. Not eligible outcomes. [pmid: 8227997].
1199 Ebrahim S, Patel N, Coats M, et al. Prevalence and severity of morbidity among Gujarati Asian elders: a controlled comparison. Fam Pract. Mar. 1991;8(1):57-62. Not eligible level of evidence. [pmid: 2044874].
1200 Eccersley AJ, Lunniss PJ, Williams NS. Unstimulated graciloplasty in traumatic faecal incontinence. Br J Surg. Aug. 1999;86(8):1071-2. Comment. [pmid: 10460647].
1201 Eckardt VF, Jung B, Fischer B, et al. Anal endosonography in healthy subjects and patients with idiopathic fecal incontinence. Dis Colon Rectum. Mar. 1994;37(3):235-42. Not eligible outcomes. [pmid: 8137670].
1202 Edwall L, Carlstrom K, Jonasson AF. Markers of collagen synthesis and degradation in urogenital tissue from women with and without stress urinary incontinence. Neurourol Urodyn. 2005;24(4):319-24. Not eligible level of evidence. [pmid: 15924353].
1203 Eekhof J, De Bock G, Schaapveld K, et al. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. Aug. 2000;17(4):329-33. Not eligible level of evidence. [pmid: 10934182].
1204 Efron JE, Corman ML, Fleshman J, et al. Safety and effectiveness of temperature-controlled radio-frequency energy delivery to the anal canal (Secca procedure) for the treatment of fecal incontinence. Dis Colon Rectum. Dec. 2003;46(12):1606-16. discussion 16–8. Not eligible target population. [pmid: 14668584].
1205 Efthimiadis C, Basdanis G, Zatagias A, et al. Manometric and clinical evaluation of patients after low anterior resection for rectal cancer. Tech Coloproctol. Nov. 2004;8(Suppl 1):s205-7. No associative hypothesis tested. [pmid: 15655624].
1206 Egawa S, Kuruma H, Suyama K, et al. Delayed recovery of urinary continence after laparoscopic radical prostatectomy. Int J Urol. Apr. 2003;10(4):207-12. Case-series. [pmid: 12657100].
1207 Egawa S, Minei S, Iwamura M, et al. Urinary continence following radical prostatectomy. Jpn J Clin Oncol. Apr. 1997;27(2):71-5. Case-series. [pmid: 9152793].
1208 Egon G, Barat M, Colombel P, et al. Implantation of anterior sacral root stimulators combined with posterior sacral rhizotomy in spinal injury patients. World J Urol. 1998;16(5):342-9. Case-series. [pmid: 9833314].
1209 Eguare EI, Neary P, Crosbie J, et al. Dynamic magnetic resonance imaging of the pelvic floor in patients with idiopathic combined fecal and urinary incontinence. J Gastrointest Surg. Jan. 2004;8(1):73-82. discussion Not eligible outcomes. [pmid: 14746838].
1210 Eire PF, Cives RV, Gago MC. Faecal incontinence in children with spina bifida: the best conservative treatment. Spinal Cord. Nov. 1998;36(11):774-6. Case-series. [pmid: 9848485].
1211 Eisenberger CF, Schoenberg M, Fitter D, et al. Orthotopic ileocolic neobladder reconstruction following radical cystectomy: history, technique and results of the Johns Hopkins experience, 1986-1998. Urol Clin North Am. Feb. 1999;26(1):149-56. ix. Case-series. [pmid: 10086056].
1212 Eisenstein SM, Engelbrecht DJ, el Masry WS. Low back pain and urinary incontinence. A hypothetical relationship. Spine. May 15. 1994;19(10):1148-52. Case-series. [pmid: 8059271].
1213 Eisman E, Tries J. A new probe for measuring electromyographic activity from multiple sites in the anal canal. Dis Colon Rectum. Oct. 1993;36(10):946-52. Case-series. [pmid: 8404387].
1214 Elabbady AA, Elabbasy WI, Arafa AF, et al. A simple technique for urinary diversion: the dismembered detubularized rectosigmoid bladder with distal colorectostomy. J Urol. Sep. 1998;160(3 Pt 1):714-7. Case-series. [pmid: 9720528].
1215 Elard S, Cicco A, Salomon L, et al. Embolization for arterial injury incurred during tension-free vaginal tape procedure. J Urol. Oct. 2002;168(4 Pt 1):1503. Case-Reports. [pmid: 12352436].
1216 Elbadawi A, Hailemariam S, Yalla SV, et al. Structural basis of geriatric voiding dysfunction. VII. Prospective ultrastructural/urodynamic evaluation of its natural evolution. J Urol. May. 1997;157(5):1814-22. Not eligible outcomes. [pmid: 9112530].
1217 Elbadawi A, Hailemariam S, Yalla SV, et al. Structural basis of geriatric voiding dysfunction. VI. Validation and update of diagnostic criteria in 71 detrusor biopsies. J Urol. May. 1997;157(5):1802-13. Not eligible outcomes. [pmid: 9112529].
1218 Elbadawi A, Yalla SV, Resnick NM. Structural basis of geriatric voiding dysfunction. III. Detrusor overactivity. J Urol. Nov. 1993;150(5 Pt 2):1668-80. Not eligible outcomes. [pmid: 8411455].
1219 el-Bahnasawy MS, Gomha MA, Shaaban AA. Urethral pressure profile following orthotopic neobladder: differences between nerve sparing and standard radical cystectomy techniques. J Urol. May. 2006;175(5):1759-63. discussion 63. Case-series. [pmid: 16600753].
1220 Eldar R, Ring H, Tshuwa M, et al. Quality of care for urinary incontinence in a rehabilitation setting for patients with stroke. Simultaneous monitoring of process and outcome. Int J Qual Health Care. Feb. 2001;13(1):57-61. Case-series. [pmid: 11330445].
1221 Elder JS. Periurethral and puboprostatic sling repair for incontinence in patients with myelodysplasia. J Urol. Aug. 1990;144(2 Pt 2):434-7. discussion 43–4. Not eligible target population. [pmid: 2374217].
1222 Eldridge GD, Walker JR, Holborn SW. Cognitive-behavioral treatment for panic disorder with gastrointestinal symptoms: a case study. J Behav Ther Exp Psychiatry. Dec. 1993;24(4):367-71. Case- Reports. [pmid: 8077455].
1223 Elgamasy AN, Lewis V, Hassouna ME, et al. Effect of transvaginal stimulation in the treatment of detrusor instability. Urol Nurs. Dec. 1996;16(4):127-30. Not eligible target population. [pmid: 9258053].
1224 ElHajj II, El-Zahabi LM, Abdul-Baki H, et al. Fecal impaction and systemic inflammatory response syndrome in a young male with cerebral palsy. South Med J. May. 2006;99(5):521-4. Case Reports. [pmid: 16711317].
1225 Elia G, Bergman A. Pelvic muscle exercises: when do they work?. Obstet Gynecol. Feb. 1993;81(2):283-6. Case-series. [pmid: 8423965].
1226 Elia G, Bergman A. Periurethral collagen implant: ultrasound assessment and prediction of outcome. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(6):335-8. Case-series. [pmid: 9203483].
1227 Elia G, Bergman J, Dye TD. Familial incidence of urinary incontinence. Am J Obstet Gynecol. Jul. 2002;187(1):53-5. Not eligible level of evidence. [pmid: 12114888].
1228 Elia G, Stewart S, Makhuli ZN, et al. Metastatic breast cancer diagnosed during a work-up for urinary incontinence: a case report. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):39-42. Case Reports. [pmid: 10207766].
1229 Eliasson K, Larsson T, Mattsson E. Prevalence of stress incontinence in nulliparous elite trampolinists. Scand J Med Sci Sports. Apr. 2002;12(2):106-10. Case-series. [pmid: 12121428].
1230 Eliasson K, Nordlander I, Mattsson E, et al. Prevalence of urinary leakage in nulliparous women with respect to physical activity and micturition habits. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):149-53. Not eligible level of evidence. [pmid: 15167991].
1231 El-Lamie IK. Preliminary experience with Mainz type II pouch in gynecologic oncology patients. Eur J Gynaecol Oncol. 2001;22(1):77-80. Case-series. [pmid: 11321503].
1232 Ellerkmann RM, Dunn JS, McBride AW, et al. A comparison of anticipated pain before and pain rating after the procedure in patients who undergo cystourethroscopy. Am J Obstet Gynecol. Jul. 2003;189(1):66-9. Not eligible outcomes. [pmid: 12861140].
1233 Ellerkmann RM, McBride AW, Dunn JS, et al. A comparison of anticipatory and postprocedure pain perception in patients who undergo urodynamic procedures. Am J Obstet Gynecol. Apr. 2004;190(4):1034-8. Not eligible outcomes. [pmid: 15118637].
1234 Elliott DS, Boone TB. Is fascia lata allograft material trustworthy for pubovaginal sling repair?. Urology. Nov 1. 2000;56(5):772-6. Case-series. [pmid: 11068297].
1235 Ellsworth PI, Webb HW, Crump JM, et al. The Malone antegrade colonic enema enhances the quality of life in children undergoing urological incontinence procedures. J Urol. Apr. 1996;155(4):1416-8. Not eligible target population. [pmid: 8632601].
1236 Ellul J, Watkins C, Barer D. Estimating total Barthel scores from just three items: the European Stroke Database ‘minimum dataset’ for assessing functional status at discharge from hospital. Age Ageing. Mar. 1998;27(2):115-22. Not eligible exposure. [pmid: 16296670].
1237 Elsergany R, Elgamasy AN, Ghoniem GM. Transurethral collagen injection for female stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(1):13-8. Not eligible target population. [pmid: 9657173].
1238 Elsergany R, Ghoniem GM. Collagen injection for intrinsic sphincteric deficiency in men: a reasonable option in selected patients. J Urol. May. 1998;159(5):1504-6. Not eligible target population. [pmid: 9554342].
1239 Elsharaby M, Abo-Farha O, Rasheed M, et al. A new technique for treatment of simple post-prostatectomy urinary incontinence: preliminary experience. J Urol. Dec. 1996;156(6):1972-4. Case-series. [pmid: 8911368].
1240 El-Sibai O, O AA. Cauterization-plication operation in the treatment of complete rectal prolapse. Tech Coloproctol. Apr. 2002;6(1):51-4. discussion 4. Case-series. [pmid: 12077642].
1241 Elton C, Stoodley BJ. Anterior anal sphincter repair: results in a district general hospital. Ann R Coll Surg Engl. Sep. 2002;84(5):321-4. Case-series. [pmid: 12398123].
1242 el-Toukhy TA, TA AE. The efficacy of laparoscopic mesh colposuspension: results of a prospective controlled study. BJU Int. Sep. 2001;88(4):361-6. Not eligible target population. [pmid: 11564022].
1243 El-Toukhy TA, Hefni M, Davies A, et al. The effect of different types of hysterectomy on urinary and sexual functions: a prospective study. J Obstet Gynaecol. Jun. 2004;24(4):420-5. Not eligible level of evidence. [pmid: 15203584].
1244 Elzevier HW, Venema PL, Lycklama a Nijeholt AA. Sexual function after tension-free vaginal tape (TVT) for stress incontinence: results of a mailed questionnaire. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):313-8. Not eligible outcomes. [pmid: 15278249].
1245 Emblem R, Dhaenens G, Stien R, et al. The importance of anal endosonography in the evaluation of idiopathic fecal incontinence. Dis Colon Rectum. Jan. 1994;37(1):42-8. Not eligible outcomes. [pmid: 8287746].
1246 Emir L, Erol D, Ak H, et al. A new technique combining both polypropylene and vaginal wall sling procedures: can it minimize the risk of urethral and vaginal erosion occurring with synthetic materials?. World J Urol. Jul. 2005;23(3):221-4. Case-series. [pmid: 15997396].
1247 Emiroglu R, Karakayall H, Sevmis S, et al. Urologic complications in 1275 consecutive renal transplantations. Transplant Proc. Feb–Mar. 2001;33(12):2016-7. Not eligible level of evidence. [pmid: 11267607].
1248 Enck P, Daublin G, Lubke HJ, et al. Long-term efficacy of biofeedback training for fecal incontinence. Dis Colon Rectum. Oct. 1994;37(10):997-1001. Case-series. [pmid: 7924721].
1249 Engberg S, McDowell BJ, Donovan N, et al. Treatment of urinary incontinence in homebound older adults: interface between research and practice. Ostomy Wound Manage 1997 Nov–Dec; 43(10):18–22, 4–6. No associative hypothesis tested
1250 Engberg S, McDowell BJ, Weber E, et al. Assessment and management of urinary incontinence among homebound older adults: a clinical trial protocol. Adv Pract Nurs Q. Fall. 1997;3(2):48-56. No associative hypothsis tested. [pmid: 9432453].
1251 Engberg SJ, Bender MA, Stilley CS. Kegels and communication. Am J Nurs. Jul. 2003;103(7):93-4. Case- Reports. [pmid: 12877134].
1252 Engberg SJ, McDowell BJ, Burgio KL, et al. Self-care behaviors of older women with urinary incontinence. J Gerontol Nurs. Aug. 1995;21(8):7-14. Not eligible outcomes.
1253 Engberg SJ, Organist L, Lafayette-Lucey A, et al. Treatment of urinary incontinence among caregiver-dependent adults. Urol Nurs 1998 Jun; 18(2):131–6, 55. No associative hypothesis tested
1254 Engel AF, Brummelkamp WH. Secondary surgery after failed postanal or anterior sphincter repair. Int J Colorectal Dis. 1994;9(4):187-90. Case-series. [pmid: 7876721].
1255 Engel AF, Kamm MA. The acute effect of straining on pelvic floor neurological function. Int J Colorectal Dis. Apr. 1994;9(1):8-12. Not eligible outcomes. [pmid: 8027627].
1256 Engel AF, Kamm MA, Bartram CI. Unwanted anal penetration as a physical cause of faecal incontinence. Eur J Gastroenterol Hepatol. Jan. 1995;7(1):65-7. Case Reports. [pmid: 7866814].
1257 Engel AF, Kamm MA, Bartram CI, et al. Relationship of symptoms in faecal incontinence to specific sphincter abnormalities. Int J Colorectal Dis. 1995;10(3):152-5. Not eligible outcomes. [pmid: 7561433].
1258 Engel AF, Kamm MA, Sultan AH, et al. Anterior anal sphincter repair in patients with obstetric trauma. Br J Surg. Aug. 1994;81(8):1231-4. Case-series. [pmid: 7953372].
1259 Engel AF, Kamm MA, Talbot IC. Progressive systemic sclerosis of the internal anal sphincter leading to passive faecal incontinence. Gut. Jun. 1994;35(6):857-9. Case Reports. [pmid: 8020821]. [pmcid: 1374896].
1260 Engel AF, Lunniss PJ, Kamm MA, et al. Sphincteroplasty for incontinence after surgery for idiopathic fistula in ano. Int J Colorectal Dis. 1997;12(6):323-5. Case-series. [pmid: 9457523].
1261 Engel AF, van Baal SJ, Brummelkamp WH. Late results of anterior sphincter plication for traumatic faecal incontinence. Eur J Surg. Nov. 1994;160(11):633-6. Case-series. [pmid: 7858048].
1262 Engel AF, van Baal SJ, Brummelkamp WH. Late results of postanal repair for idiopathic faecal incontinence. Eur J Surg. Nov. 1994;160(11):637-40. Case-series. [pmid: 7858049].
1263 Engel BT, Burgio LD, McCormick KA, et al. Behavioral treatment of incontinence in the long-term care setting. J Am Geriatr Soc. Mar. 1990;38(3):361-3. No associative hypothesis tested. [pmid: 2107245].
1264 Engel JD, Jacobs D, Konsur B, et al. Urodynamic evaluation of the human bladder response to an increase in outlet resistance. Neurourol Urodyn. 2002;21(6):524-8. Case-series. [pmid: 12382241].
1265 Engst C, Chhokar R, Robinson D, et al. Implementation of a scheduled toileting program in a long term care facility: evaluating the impact on injury risk to caregiving staff. Aaohn J. Oct. 2004;52(10):427-35. Not eligible outcomes. [pmid: 15508857].
1266 Engstrom G, Henningsohn L, Steineck G, et al. Self-assessed health, sadness and happiness in relation to the total burden of symptoms from the lower urinary tract. BJU Int. Apr. 2005;95(6):810-5. Not eligible outcomes. [pmid: 15794788].
1267 Engstrom G, Walker-Engstrom ML, Henningsohn L, et al. Prevalence of distress and symptom severity from the lower urinary tract in men: a population-based study with the DAN-PSS questionnaire. Fam Pract. Dec. 2004;21(6):617-22. Not eligible outcomes. [pmid: 15465878].
1268 Enriquez-Navascues JM, Devesa-Mugica JM. Traumatic anal incontinence. Role of unilateral gluteus maximus transposition supplementing and supporting direct anal sphincteroplasty. Dis Colon Rectum. Aug. 1994;37(8):766-9. Case-reports. [pmid: 8055720].
1269 Enzelsberger H, Helmer H, Kurz C. Intravesical instillation of oxybutynin in women with idiopathic detrusor instability: a randomised trial. Br J Obstet Gynaecol. Nov. 1995;102(11):929-30. Not eligible exposure. [pmid: 8534633].
1270 Enzelsberger H, Helmer H, Schatten C. Comparison of Burch and lyodura sling procedures for repair of unsuccessful incontinence surgery. Obstet Gynecol. Aug. 1996;88(2):251-6. Not eligible target population. [pmid: 8692511].
1271 Epanomeritakis E, Koutsoumbi P, Tsiaoussis I, et al. Impairment of anorectal function in diabetes mellitus parallels duration of disease. Dis Colon Rectum. Nov. 1999;42(11):1394-400. Not eligible outcomes. [pmid: 10566526].
1272 Erata YE, Kilic B, Guclu S, et al. Risk factors for pelvic surgery. Arch Gynecol Obstet. Nov. 2002;267(1):14-8. Not eligible level of evidence. [pmid: 12410367].
1273 Erickson DR. Glomerulations in women with urethral sphincter deficiency: report of 2 cases [corrected]. J Urol. Mar. 1995;153(3 Pt 1):728-9. Case Reports. [pmid: 7861522].
1274 Eriksen BC, Hagen B, Eik-Nes SH, et al. Long-term effectiveness of the Burch colposuspension in female urinary stress incontinence. Acta Obstet Gynecol Scand. 1990;69(1):45-50. Case-series. [pmid: 2346079].
1275 Eriksen BC, Sandvik H, Hunskaar S. Management of urinary incontinence in gynecological practice in Norway. Acta Obstet Gynecol Scand. 1990;69(6):515-9. Not eligible target population. [pmid: 2284902].
1276 Ertunc D, Tok EC, Pata O, et al. Is stress urinary incontinence a familial condition?. Acta Obstet Gynecol Scand. Oct. 2004;83(10):912-6. Not eligible level of evidence. [pmid: 15453885].
1277 Eterovic D, Strinic T, Dujic Z, et al. Blood gases and sex hormones in women with and without genital descensus. Respiration. 1999;66(5):400-6. Not eligible outcomes. [pmid: 10516535].
1278 Ethans KD, Nance PW, Bard RJ, et al. Efficacy and safety of tolterodine in people with neurogenic detrusor overactivity. J Spinal Cord Med. 2004;27(3):214-8. Not eligible exposure. [pmid: 15478523].
1279 Etus V, Akansel G, Ilbay K, et al. Multiple sclerosis and coexisting intradural extramedullary spinal cord tumour: a case report. Neurol Sci. Sep. 2002;23(3):119-22. Case Reports. [pmid: 12391496].
1280 Evans D. Discreet products for women with urinary incontinence. Nurs Times 2005 May 3–9; 101(18):56–7, 9. Case-reports
1281 Evans D. Lifestyle solutions for men with continence problems. Nurs Times 2005 Jan 11–17; 101(2):61–2, 4. Case-reports
1282 Evans JW, Christmas TJ. Detrusor instability following colchicine therapy. Br J Urol. May. 1991;67(5):552-4. Case Reports. [pmid: 2039931].
1283 Evans RW, Nasir N Jr. Case report: Dr. Lecter's convulsive syncope. MedGenMed. Oct 1. 2001;3(5):7. Case Reports. [pmid: 11976606].
1284 Everaert K, De Ridder D, Baert L, et al. Patient satisfaction and complications following sacral nerve stimulation for urinary retention, urge incontinence and perineal pain: a multicenter evaluation. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(4):231-5. discussion 6. Not eligible target population. [pmid: 11005475].
1285 Everaert K, Derie A, Van Laere M, et al. Bilateral S3 nerve stimulation, a minimally invasive alternative treatment for postoperative stress incontinence after implantation of an anterior root stimulator with posterior rhizotomy: a preliminary observation. Spinal Cord. Apr. 2000;38(4):262-4. Case Reports. [pmid: 10822398].
1286 Eyman RK, Grossman HJ, Chaney RH, et al. The life expectancy of profoundly handicapped people with mental retardation. N Engl J Med. Aug 30. 1990;323(9):584-9. Not eligible outcomes. [pmid: 2143270].
1287 Ezzat IM. Sling operations in the treatment of stress urinary incontinence: how to adjust sling tension. J Obstet Gynaecol Res. Dec. 2003;29(6):374-9. Case-series. [pmid: 14641684].
1288 Ezzat MI. Abdomino-perineal approach for management of traumatic strictured posterior urethra. Int Urol Nephrol. 1990;22(5):447-53. Case-series. [pmid: 2076934].
1289 Fader M, Clarke-O'Neill S, Cook D, et al. Management of night-time urinary incontinence in residential settings for older people: an investigation into the effects of different pad changing regimes on skin health. J Clin Nurs. May. 2003;12(3):374-86. Not eligible outcomes. [pmid: 12709112].
1290 Fader M, Moore KN, Cottenden AM, et al. Coated catheters for intermittent catheterization: smooth or sticky?. BJU Int. Sep. 2001;88(4):373-7. Not eligible outcomes. [pmid: 11564024].
1291 Fader M, Pettersson L, Dean G, et al. Sheaths for urinary incontinence: a randomized crossover trial. BJU Int. Sep. 2001;88(4):367-72. Not eligible outcomes. [pmid: 11564023].
1292 Faerber GJ. Endoscopic collagen injection therapy in elderly women with type I stress urinary incontinence. J Urol. Feb. 1996;155(2):512-4. Not eligible target population. [pmid: 8558648].
1293 Faerber GJ. Urethral diverticulectomy and pubovaginal sling for simultaneous treatment of urethral diverticulum and intrinsic sphincter deficiency. Tech Urol. Dec. 1998;4(4):192-7. Case-series. [pmid: 9892000].
1294 Faerber GJ, Richardson TD. Long-term results of transurethral collagen injection in men with intrinsic sphincter deficiency. J Endourol. Aug. 1997;11(4):273-7. Case-series. [pmid: 9376848].
1295 Fahn S, Brin MF, Dwork AJ, et al. Case 1, 1996: rapidly progressive parkinsonism, incontinence, impotency, and levodopa-induced moaning in a patient with multiple myeloma. Mov Disord. May. 1996;11(3):298-310. Case Reports. [pmid: 8723148].
1296 Fainsinger RL, MacEachern T, Hanson J, et al. The use of urinary catheters in terminally ill cancer patients. J Pain Symptom Manage. Aug. 1992;7(6):333-8. Case-series. [pmid: 1517648].
1297 Falconer C, Blomgren B, Johansson O, et al. Different organization of collagen fibrils in stress-incontinent women of fertile age. Acta Obstet Gynecol Scand. Jan. 1998;77(1):87-94. Not eligible outcomes. [pmid: 9492726].
1298 Falconer C, Ekman-Ordeberg G, Blomgren B, et al. Paraurethral connective tissue in stress-incontinent women after menopause. Acta Obstet Gynecol Scand. Jan. 1998;77(1):95-100. Not eligible outcomes. [pmid: 9492727].
1299 Falconer C, Soderberg M, Blomgren B, et al. Influence of different sling materials on connective tissue metabolism in stress urinary incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S19-23. Case-series. [pmid: 11450975].
1300 Falconio MA, Kokoszka JS, Prasad ML. Anorectal manometry. Gastroenterol Nurs. Dec. 1992;15(3):110-3. Not eligible outcomes. [pmid: 1472555].
1301 Falk PM, Blatchford GJ, Cali RL, et al. Transanal ultrasound and manometry in the evaluation of fecal incontinence. Dis Colon Rectum. May. 1994;37(5):468-72. Question 4. [pmid: 8181409].
1302 Falkert A, Seelbach-Gobel B. TVT versus TOT for surgical treatment of female stress urinary incontinence. Int J Gynaecol Obstet. Jan. 2007;96(1):40-1. Comment. [pmid: 17187789].
1303 Fall M, Geirsson G. Positive ice-water test: a predictor of neurological disease?. World J Urol. 1996;14(Suppl 1):S51-4. Case Reports. [pmid: 8738412].
1304 Faltin DL, Boulvain M, Irion O, et al. Diagnosis of anal sphincter tears by postpartum endosonography to predict fecal incontinence. Obstet Gynecol. May. 2000;95(5):643-7. Not eligible outcomes. [pmid: 10775721].
1305 Fantin AC, Hetzer FH, Christ AD, et al. Influence of stapler haemorrhoidectomy on anorectal function and on patients' acceptance. Swiss Med Wkly. Jan 26. 2002;132(34):38-42. Case-series. [pmid: 11953904].
1306 Farag A. Use of the Hagen-Poiseuille law: a new mathematical approach for the integration and evaluation of anorectal physiological testing in patients with faecal incontinence and pelvic dyschezia and in normal controls. Eur Surg Res. 1998;30(4):279-89. Not eligible outcomes. [pmid: 9704755].
1307 Faria CA, Sartori MG, Baracat EC, et al. Effects of tamoxifen on Doppler velocimetry parameters of periurethral vessels in postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):56-9. discussion 9. Not eligible outcomes. [pmid: 15338114].
1308 Farid M, Moneim HA, Mahdy T, et al. Augmented unilateral gluteoplasty with fascia lata graft in fecal incontinence. Tech Coloproctol. Apr. 2003;7(1):23-8. discussion 8. Case-series. [pmid: 12750951].
1309 Faridi A, Willis S, Schelzig P, et al. Anal sphincter injury during vaginal delivery—an argument for cesarean section on request?. J Perinat Med. 2002;30(5):379-87. Case-series. [pmid: 12442601].
1310 Farouk R, Bartolo DC. The clinical contribution of integrated laboratory and ambulatory anorectal physiology assessment in faecal incontinence. Int J Colorectal Dis. Jul. 1993;8(2):60-5. Not eligible outcomes. [pmid: 8409687].
1311 Farouk R, Bartolo DC. The use of endoluminal ultrasound in the assessment of patients with faecal incontinence. J R Coll Surg Edinb. Oct. 1994;39(5):312-8. Case-series. [pmid: 7861344].
1312 Farouk R, Drew PJ, Duthie GS, et al. Disruption of the internal anal sphincter can occur after transanal stapling. Br J Surg. Oct. 1996;83(10):1400. Case-series. [pmid: 8944441].
1313 Farouk R, Duthie GS, Bartolo DC. Recovery of the internal anal sphincter and continence after restorative proctocolectomy. Br J Surg. Jul. 1994;81(7):1065-8. Case-series. [pmid: 7922067].
1314 Farouk R, Duthie GS, Bartolo DC, et al. Restoration of continence following rectopexy for rectal prolapse and recovery of the internal anal sphincter electromyogram. Br J Surg. May. 1992;79(5):439-40. Case-series. [pmid: 1596729].
1315 Farouk R, Duthie GS, MacGregor AB, et al. Evidence of electromechanical dissociation of the internal anal sphincter in idiopathic fecal incontinence. Dis Colon Rectum. Jun. 1994;37(6):595-601. Not eligible outcomes. [pmid: 8200240].
1316 Farouk R, Duthie GS, MacGregor AB, et al. Rectoanal inhibition and incontinence in patients with rectal prolapse. Br J Surg. May. 1994;81(5):743-6. Not eligible outcomes. [pmid: 8044569].
1317 Farouk R, Duthie GS, Pryde A, et al. Internal anal sphincter dysfunction in neurogenic faecal incontinence. Br J Surg. Feb. 1993;80(2):259-61. Not eligible outcomes. [pmid: 8443675].
1318 Farouk R, Pemberton JH, Wolff BG, et al. Functional outcomes after ileal pouch-anal anastomosis for chronic ulcerative colitis. Ann Surg. Jun. 2000;231(6):919-26. Not eligible level of evidence. [pmid: 10816636]. [pmcid: 1421082].
1319 Farrell SA, Baydock S, Amir B, et al. Effectiveness of a new self-positioning pessary for the management of urinary incontinence in women. Am J Obstet Gynecol 2007 May; 196(5):474 e1–8. Case-series
1320 Farrell TA, Wallace M, Hicks ME. Long-term results of transrenal ureteral occlusion with use of Gianturco coils and gelatin sponge pledgets. J Vasc Interv Radiol. May–Jun. 1997;8(3):449-52. Case-series. [pmid: 9152920].
1321 Faucheron JL, Bost R, Duffournet V, et al. Sacral neuromodulation in the treatment of severe anal incontinence. Forty consecutive cases treated in one institution. Gastroenterol Clin Biol. May. 2006;30(5):669-72. Case-series. [pmid: 16801889].
1322 Faucheron JL, Hannoun L, Thome C, et al. Is fecal continence improved by nonstimulated gracilis muscle transposition?. Dis Colon Rectum. Oct. 1994;37(10):979-83. Not eligible target population. [pmid: 7924718].
1323 Faundes A, Guarisi T, Pinto-Neto AM. The risk of urinary incontinence of parous women who delivered only by cesarean section. Int J Gynaecol Obstet. Jan. 2001;72(1):41-6. Not eligible level of evidence. [pmid: 11146076].
1324 Fazio VW, O'Riordain MG, Lavery IC, et al. Long-term functional outcome and quality of life after stapled restorative proctocolectomy. Ann Surg. Oct. 1999;230(4):575-84. discussion 84–6. Not eligible target population. [pmid: 10522727]. [pmcid: 1420906].
1325 Fazio VW, Tjandra JJ. Transanal mucosectomy. Ileal pouch advancement for anorectal dysplasia or inflammation after restorative proctocolectomy. Dis Colon Rectum. Oct. 1994;37(10):1008-11. Case- Reports. [pmid: 7924706].
1326 Fehrmann-Zumpe P, Karbe K, Blessman G. Using flavoxate as primary medication for patients suffering from urge symptomatology. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(2):91-5. Case-series. [pmid: 10384969].
1327 Feigenberg SJ, Lee WR, Desilvio ML, et al. Health-related quality of life in men receiving prostate brachytherapy on RTOG 98-05. Int J Radiat Oncol Biol Phys. Jul 15. 2005;62(4):956-64. Case-series. [pmid: 15989995].
1328 Feldman EL, Jaffe A, Galambos N, et al. Clinical practice guidelines on depression: awareness, attitudes, and content knowledge among family physicians in New York. Arch Fam Med. Jan–Feb. 1998;7(1):58-62. Guideline. [pmid: 9443701].
1329 Feldner PC Jr, Kati LM, Sartori MG, et al. Sulfated glycosaminoglycans of the periurethral tissue in women with and without stress urinary incontinence, according to genital prolapse stage. Eur J Obstet Gynecol Reprod Biol. Jun 1. 2006;126(2):250-4. Case-series. [pmid: 16314024].
1330 Felt-Bersma RJ, Cuesta MA, Koorevaar M. Anal sphincter repair improves anorectal function and endosonographic image. A prospective clinical study. Dis Colon Rectum. Aug. 1996;39(8):878-85. Case-series. [pmid: 8756843].
1331 Felt-Bersma RJ, Cuesta MA, Koorevaar M, et al. Anal endosonography: relationship with anal manometry and neurophysiologic tests. Dis Colon Rectum. Oct. 1992;35(10):944-9. Not eligible outcomes. [pmid: 1395981].
1332 Felt-Bersma RJ, Klinkenberg-Knol EC, Meuwissen SG. Anorectal function investigations in incontinent and continent patients. Differences and discriminatory value. Dis Colon Rectum. Jun. 1990;33(6):479-85. discussion 85–6. Not eligible outcomes. [pmid: 2351000].
1333 Felt-Bersma RJ, Poen AC, Cuesta MA, et al. Anal sensitivity test: what does it measure and do we need it? Cause or derivative of anorectal complaints. Dis Colon Rectum. Jul. 1997;40(7):811-6. Not eligible outcomes. [pmid: 9221858].
1334 Felt-Bersma RJ, Sloots CE, Poen AC, et al. Rectal compliance as a routine measurement: extreme volumes have direct clinical impact and normal volumes exclude rectum as a problem. Dis Colon Rectum. Dec. 2000;43(12):1732-8. Not eligible outcomes. [pmid: 11156459].
1335 Felt-Bersma RJ, van Baren R, Koorevaar M, et al. Unsuspected sphincter defects shown by anal endosonography after anorectal surgery. A prospective study. Dis Colon Rectum. Mar. 1995;38(3):249-53. Not eligible outcomes. [pmid: 7882786].
1336 Feneley MR, Walsh PC. Incontinence after radical prostatectomy. Lancet. Jun 19. 1999;353(9170):2091-2. Comment. [pmid: 10382690].
1337 Fengler SA, Pearl RK, Prasad ML, et al. Management of recurrent rectal prolapse. Dis Colon Rectum. Jul. 1997;40(7):832-4. [pmid: 9221862].
1338 Fenig DM, Slova D, Lepor H. Postoperative blood loss predicts the development of urinary extravasation on cystogram following radical retropubic prostatectomy. J Urol. Jan. 2006;175(1):146-50. discussion 50. Not eligible outcomes. [pmid: 16406894].
1339 Fenn N, Conn IG, German KA, et al. Complications of clam enterocystoplasty with particular reference to urinary tract infection. Br J Urol. Apr. 1992;69(4):366-8. Case-series. [pmid: 1581806].
1340 Feretis C, Benakis P, Dailianas A, et al. Implantation of microballoons in the management of fecal incontinence. Dis Colon Rectum. Nov. 2001;44(11):1605-9. Not eligible target population. [pmid: 11711731].
1341 Ferland RD, Rosenblatt P. Ureteral compromise after laparoscopic Burch colpopexy. J Am Assoc Gynecol Laparosc. May. 1999;6(2):217-9. Case- Reports. [pmid: 10226137].
1342 Fernandez-Fraga X, Azpiroz F, Aparici A, et al. Predictors of response to biofeedback treatment in anal incontinence. Dis Colon Rectum. Sep. 2003;46(9):1218-25. Case-series. [pmid: 12972966].
1343 Fernandez-Fraga X, Azpiroz F, Malagelada JR. Significance of pelvic floor muscles in anal incontinence. Gastroenterology. Nov. 2002;123(5):1441-50. Not eligible outcomes. [pmid: 12404218].
1344 Ferrara A, De Jesus S, Gallagher JT, et al. Time-related decay of the benefits of biofeedback therapy. Tech Coloproctol. Dec. 2001;5(3):131-5. Case-series. [pmid: 11875679].
1345 Ferrara A, Lujan JH, Cebrian J, et al. Clinical, manometric, and EMG characteristics of patients with fecal incontinence. Tech Coloproctol. Apr. 2001;5(1):13-8. Not eligible outcomes. [pmid: 11793254].
1346 Ferrara A, Pemberton JH, Grotz RL, et al. Motor determinants of incontinence after ileal pouch-anal anastomosis. Br J Surg. Feb. 1994;81(2):285-8. Not eligible outcomes. [pmid: 8156361].
1347 Ferrari A, Frigerio L. The triangular vaginal patch sling for stress urinary incontinence and hypermobile urethra. Am J Obstet Gynecol. Dec. 1997;177(6):1426-31. Case-series. [pmid: 9423746].
1348 Fialkow MF, Lentz GM, Miller EA, et al. Complications from transvaginal pubovaginal slings using bone anchor fixation. Urology. Dec. 2004;64(6):1127-32. Case-series. [pmid: 15596184].
1349 Ficarra V, Novara G, Galfano A, et al. Twelve-month self-reported quality of life after retropubic radical prostatectomy: a prospective study with Rand 36-Item Health Survey (Short Form-36). BJU Int. Feb. 2006;97(2):274-8. Not eligible outcomes. [pmid: 16430628].
1350 Fichera A, Michelassi F. Long-term prospective assessment of functional results after proctectomy with coloanal anastomosis. J Gastrointest Surg. Mar–Apr. 2001;5(2):153-7. Case-series. [pmid: 11331477].
1351 Fielding JR. Practical MR imaging of female pelvic floor weakness. Radiographics. Mar–Apr. 2002;22(2):295-304. No associative hypothesis tested. [pmid: 11896220].
1352 Fielding JR, Dumanli H, Schreyer AG, et al. MR-based three-dimensional modeling of the normal pelvic floor in women: quantification of muscle mass. AJR Am J Roentgenol. Mar. 2000;174(3):657-60. Not eligible outcomes. [pmid: 10701604].
1353 Fielding JR, Griffiths DJ, Versi E, et al. MR imaging of pelvic floor continence mechanisms in the supine and sitting positions. AJR Am J Roentgenol. Dec. 1998;171(6):1607-10. Not eligible exposure. [pmid: 9843296].
1354 Fielding JR, Lee JH, Dubeau CE, et al. Voiding cystourethrography findings in elderly women with urge incontinence. J Urol. Apr. 2000;163(4):1216-8. Not eligible outcomes. [pmid: 10737500].
1355 Fielding JR, Versi E, Mulkern RV, et al. MR imaging of the female pelvic floor in the supine and upright positions. J Magn Reson Imaging. Nov–Dec. 1996;6(6):961-3. Not eligible target population. [pmid: 8956147].
1356 Figueroa TE, Sabogal L, Helal M, et al. The tapered and reimplanted small bowel as a variation of the Mitrofanoff procedure: preliminary results. J Urol. Jul. 1994;152(1):73-5. Case-series. [pmid: 8201693].
1357 Filiz TM, Uludag C, Cinar N, et al. Risk factors for urinary incontinence in Turkish women. A cross-sectional study. Saudi Med J. Nov. 2006;27(11):1688-92. Not eligible level of evidence. [pmid: 17106542].
1358 Fink D, Perucchini D, Schaer GN, et al. The role of the frequency-volume chart in the differential diagnostic of female urinary incontinence. Acta Obstet Gynecol Scand. Mar. 1999;78(3):254-7. Not eligible outcomes. [pmid: 10078589].
1359 Fink RL, Roberts LJ, Scott M. The role of manometry, electromyography and radiology in the assessment of faecal incontinence. Aust N Z J Surg. Dec. 1992;62(12):951-8. Not eligible outcomes. [pmid: 1456906].
1360 Finkelstein MM, Skelly J, Kaczorowski J, et al. Incontinence Quality of Life Instrument in a survey of primary care physicians. J Fam Pract. Nov. 2002;51(11):952. Not eligible level of evidence.
1361 Fiori M, Gunelli R, Mercuriali M, et al. Tension-free vaginal tape and female stress incontinence: further evidence of effectiveness. Urol Int. 2004;72(4):325-8. Case-series. [pmid: 15153731].
1362 Fischer JR, Berg PH. Urinary incontinence in United States Air Force female aircrew. Obstet Gynecol. Oct. 1999;94(4):532-6. Not eligible level of evidence. [pmid: 10511354].
1363 Fischer MC, Huckabay C, Nitti VW. The male perineal sling: assessment and prediction of outcome. J Urol. Apr. 2007;177(4):1414-8. Case-series. [pmid: 17382743].
1364 Fischer W, Baessler K. Postpartum pelvic floor conditioning using vaginal cones: not only for prophylaxis against urinary incontinence and descensus. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(4):208-14. Case-series. [pmid: 10895806].
1365 Fischer W, Linde A. Pelvic floor findings in urinary incontinence—results of conditioning using vaginal cones. Acta Obstet Gynecol Scand. May. 1997;76(5):455-60. Not eligible target population. [pmid: 9197449].
1366 Fisher K, Riolo L. What is the evidence regarding specific methods of pelvic floor exercise for a patient with urinary stress incontinence and mild anterior wall prolapse?. Phys Ther. Aug. 2004;84(8):744-53. Review. [pmid: 15283625].
1367 Fishman IJ, Scott FB. Pregnancy in patients with the artificial urinary sphincter. J Urol. Aug. 1993;150(2 Pt 1):340-1. Case-series. [pmid: 8326558].
1368 Fishwick JE, Gough DC, O'Flynn KJ. The Mitrofanoff procedure: does it last?. BJU Int. Mar. 2000;85(4):496-7. Case-series. [pmid: 10691832].
1369 Fitzgerald JF, Smith DM, Martin DK, et al. Replication of the multidimensionality of activities of daily living. J Gerontol. Jan. 1993;48(1):S28-31. Not eligible outcomes. [pmid: 8418153].
1370 Fitzgerald MP, Ayuste D, Brubaker L. How do urinary diaries of women with an overactive bladder differ from those of asymptomatic controls?. BJU Int. Aug. 2005;96(3):365-7. Not eligible outcomes. [pmid: 16042731].
1371 FitzGerald MP, Blazek B, Brubaker L. Complex repetitive discharges during urethral sphincter EMG: clinical correlates. Neurourol Urodyn. 2000;19(5):577-83. Not eligible outcomes. [pmid: 11002300].
1372 FitzGerald MP, Kenton K, Shott S, et al. Responsiveness of quality of life measurements to change after reconstructive pelvic surgery. Am J Obstet Gynecol. Jul. 2001;185(1):20-4. Not eligible outcomes. [pmid: 11483898].
1373 Fitzgerald MP, Mollenhauer J, Brubaker L. Failure of allograft suburethral slings. BJU Int. Nov. 1999;84(7):785-8. Case-series. [pmid: 10532972].
1374 FitzGerald MP, Russell B, Hale D, et al. Ultrastructure of detrusor and urethral smooth muscle in women with urinary incontinence. Am J Obstet Gynecol. Apr. 2000;182(4):879-84. Not eligible outcomes. [pmid: 10764466].
1375 Fitzgerald MP, Thom DH, Wassel-Fyr C, et al. Childhood urinary symptoms predict adult overactive bladder symptoms. J Urol. Mar. 2006;175(3 Pt 1):989-93. Not eligible outcomes. [pmid: 16469599]. [pmcid: 1820589].
1376 Fitzgerald MP, Weber AM, Howden N, et al. Risk factors for anal sphincter tear during vaginal delivery. Obstet Gynecol. Jan. 2007;109(1):29-34. Not eligible level of evidence. [pmid: 17197584].
1377 Fitzgerald ST, Palmer MH, Berry SJ, et al. Urinary incontinence. Impact on working women. Aaohn J. Mar. 2000;48(3):112-8. Not eligible level of evidence. [pmid: 10846967].
1378 Fitzgerald ST, Palmer MH, Kirkland VL, et al. The impact of urinary incontinence in working women: a study in a production facility. Women Health. 2002;35(1):1-16. Not eligible level of evidence.
1379 Fitzpatrick M, Fynes M, Cassidy M, et al. Prospective study of the influence of parity and operative technique on the outcome of primary anal sphincter repair following obstetrical injury. Eur J Obstet Gynecol Reprod Biol. Apr. 2000;89(2):159-63. Not eligible outcomes. [pmid: 10725575].
1380 Fleishman R, Heilbrun G, Mandelson J, et al. Improving the quality of institutional care of urinary incontinence among the elderly: a challenge for governmental regulation. Int J Health Care Qual Assur Inc Leadersh Health Serv. 1999;12(23):105-19. Not eligible level of evidence. [pmid: 10537853].
1381 Fleshman JW, Dreznik Z, Fry RD, et al. Anal sphincter repair for obstetric injury: manometric evaluation of functional results. Dis Colon Rectum. Dec. 1991;34(12):1061-7. Case-series. [pmid: 1959455].
1382 Fleshman JW, Peters WR, Shemesh EI, et al. Anal sphincter reconstruction: anterior overlapping muscle repair. Dis Colon Rectum. Sep. 1991;34(9):739-43. Case-series. [pmid: 1914735].
1383 Fleshner N, Herschorn S. The artificial urinary sphincter for post-radical prostatectomy incontinence: impact on urinary symptoms and quality of life. J Urol. Apr. 1996;155(4):1260-4. Case-series. [pmid: 8632546].
1384 Fletcher JG, Busse RF, Riederer SJ, et al. Magnetic resonance imaging of anatomic and dynamic defects of the pelvic floor in defecatory disorders. Am J Gastroenterol. Feb. 2003;98(2):399-411. No associative hypothesis tested. [pmid: 12591061].
1385 Flood HD, Malhotra SJ, O'Connell HE, et al. Long-term results and complications using augmentation cystoplasty in reconstructive urology. Neurourol Urodyn. 1995;14(4):297-309. Case-series. [pmid: 7581466].
1386 Flynn L, Cell P, Luisi E. Effectiveness of pelvic muscle exercises in reducing urge incontinence among community residing elders. J Gerontol Nurs. May. 1994;20(5):23-7. Comment.
1387 Flynn MK, Webster GD, Amundsen CL. The effect of botulinum-A toxin on patients with severe urge urinary incontinence. J Urol. Dec. 2004;172(6 Pt 1):2316-20. Not eligible target population. [pmid: 15538257].
1388 Fokdal L, Honore H, Hoyer M, et al. Dose-volume histograms associated to long-term colorectal functions in patients receiving pelvic radiotherapy. Radiother Oncol. Feb. 2005;74(2):203-10. Case-series. [pmid: 15734208].
1389 Foldspang A, Mommsen S. Adult female urinary incontinence and childhood bedwetting. J Urol. Jul. 1994;152(1):85-8. Not eligible exposure. [pmid: 8201696].
1390 Foldspang A, Mommsen S. The International Continence Society (ICS) incontinence definition: is the social and hygienic aspect appropriate for etiologic research?. J Clin Epidemiol. Sep. 1997;50(9):1055-60. Not eligible level of evidence. [pmid: 9363040].
1391 Foley CL, Bott SR, Thomas K, et al. A large prostate at radical retropubic prostatectomy does not adversely affect cancer control, continence or potency rates. BJU Int. Sep. 2003;92(4):370-4. Case Series. [pmid: 12930421].
1392 Fonda D. Improving management of urinary incontinence in geriatric centres and nursing homes. Victorian Geriatricians Peer Review Group. Aust Clin Rev. 1990;10(2):66-71. Not eligible level of evidence. [pmid: 2078154].
1393 Fonda D, Woodward M, D'Astoli M, et al. Sustained improvement of subjective quality of life in older community-dwelling people after treatment of urinary incontinence. Age Ageing. Jul. 1995;24(4):283-6. No associative hypothesis tested. [pmid: 7484483].
1394 Fontaine E, Ben Mouelli S, Thomas L, et al. Urinary continence after salvage radiation therapy following radical prostatectomy, assessed by a self-administered questionnaire: a prospective study. BJU Int. Sep. 2004;94(4):521-3. Case-Series. [pmid: 15329104].
1395 Fontaine E, Bendaya S, Desert JF, et al. Combined modified rectus fascial sling and augmentation ileocystoplasty for neurogenic incontinence in women. J Urol. Jan. 1997;157(1):109-12. Case-series. [pmid: 8976228].
1396 Fontaine E, Hajri M, Rhein F, et al. Reappraisal of endoscopic sphincterotomy for post-traumatic neurogenic bladder: a prospective study. J Urol. Jan. 1996;155(1):277-80. Case-series. [pmid: 7490855].
1397 Fontaine E, Izadifar V, Barthelemy Y, et al. Urinary continence following radical prostatectomy assessed by a self-administered questionnaire. Eur Urol. Feb. 2000;37(2):223-7. Case-series. [pmid: 10705203].
1398 Forbat L. Listening to carers talking about the subjects of continence and toileting. Nurs Times. Jan 13–19. 2004;100(2):46-9. Not eligible target population.
1399 Foreman MD, Theis SL, Anderson MA. Adverse events in the hospitalized elderly. Clin Nurs Res. Aug. 1993;2(3):360-70. Case-series. [pmid: 8401247].
1400 Formenti SC, Lieskovsky G, Simoneau AR, et al. Impact of moderate dose of postoperative radiation on urinary continence and potency in patients with prostate cancer treated with nerve sparing prostatectomy. J Urol. Feb. 1996;155(2):616-9. Case-series. [pmid: 8558674].
1401 Formenti SC, Lieskovsky G, Skinner D, et al. Update on impact of moderate dose of adjuvant radiation on urinary continence and sexual potency in prostate cancer patients treated with nerve-sparing prostatectomy. Urology. Sep 1. 2000;56(3):453-8. Case-series. [pmid: 10962314].
1402 Fornell EK, Berg G, Hallbook O, et al. Clinical consequences of anal sphincter rupture during vaginal delivery. J Am Coll Surg. Dec. 1996;183(6):553-8. Case-series. [pmid: 8957456].
1403 Fornell EU, Matthiesen L, Sjodahl R, et al. Obstetric anal sphincter injury ten years after: subjective and objective long term effects. Bjog. Mar. 2005;112(3):312-6. Case-series. [pmid: 15713145].
1404 Forster JA, Thomas WM. Patient preferences and side effects experienced with oral bowel preparations versus self-administered phosphate enema. Ann R Coll Surg Engl. May. 2003;85(3):185-6. Not eligible outcomes. [pmid: 12831492]. [pmcid: 1964375].
1405 Forte F, Maturo G, Catania A, et al. Retroperitoneal lipoma. Unusual presentation with detrusor instability. Minerva Urol Nefrol. Jun. 2002;54(2):131-3. Case Reports. [pmid: 12070462].
1406 Fossaluzza V, Di Benedetto P, Zampa A, et al. Misoprostol-induced urinary incontinence. J Intern Med. Nov. 1991;230(5):463-4. Case Reports. [pmid: 1940783].
1407 Fourie T, Cohen PL. Delayed bowel erosion by tension-free vaginal tape (TVT). Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):362-4. Case Reports. [pmid: 14618319].
1408 Fourie T, Ramphal S. Aerosol caps and vesicovaginal fistulas. Int J Gynaecol Obstet. Jun. 2001;73(3):275-6. Case Reports. [pmid: 11376679].
1409 Fournier C, Corcos J. Collagen injections in difficult cases of stress urinary incontinence: study results. Urol Nurs. Dec. 1996;16(4):123-6. Not eligible target population. [pmid: 9258052].
1410 Fowler AL, Mills A, Durdey P, et al. Single-fiber electromyography correlates more closely with incontinence scores than pudendal nerve terminal motor latency. Dis Colon Rectum. Dec. 2005;48(12):2309-12. Not eligible level of evidence. [pmid: 16228833].
1411 Fowler EM, Ouslander J, Papen J. Managing incontinence in the nursing home population. J Enterostomal Ther. Mar–Apr. 1990;17(2):77-86. [pmid: 2324386].
1412 Fox M, Schwizer W, Menne D, et al. The physical properties of rectal contents have effects on anorectal continence: insights from a study into the cause of fecal spotting on orlistat. Dis Colon Rectum. Dec. 2004;47(12):2147-56. Not eligible target population. [pmid: 15657667].
1413 Fox M, Stutz B, Menne D, et al. The effects of loperamide on continence problems and anorectal function in obese subjects taking orlistat. Dig Dis Sci. Sep. 2005;50(9):1576-83. Not eligible outcomes. [pmid: 16133954].
1414 Fox M, Thumshirn M, Menne D, et al. The pathophysiology of faecal spotting in obese subjects during treatment with orlistat. Aliment Pharmacol Ther. Feb 1. 2004;19(3):311-21. Not eligible outcomes. [pmid: 14984378].
1415 Fox PD, Coleman E. Managing common geriatric conditions. Healthplan. Mar–Apr. 2002;43(2):47-53. Comment. [pmid: 11961924].
1416 Foxman B, Somsel P, Tallman P, et al. Urinary tract infection among women aged 40 to 65: behavioral and sexual risk factors. J Clin Epidemiol. Jul. 2001;54(7):710-8. Not eligible outcomes. [pmid: 11438412].
1417 Franco I, Kolligian M, Reda EF, et al. The importance of catheter size in the achievement of urinary continence in patients undergoing a Young-Dees-Leadbetter procedure. J Urol. Aug. 1994;152(2 Pt 2):710-2. Not eligible target population. [pmid: 8022001].
1418 Francois Y, Descos L, Vignal J. Conservative treatment of low rectovaginal fistula in Crohn's disease. Int J Colorectal Dis. Feb. 1990;5(1):12-4. Case-series. [pmid: 2313152].
1419 Frang D, Pajor L. Radical prostatectomy and complications. Int Urol Nephrol. 1990;22(4):349-57. Case-series. [pmid: 2228497].
1420 Frankenburg FR, Zanarini MC. The association between borderline personality disorder and chronic medical illnesses, poor health-related lifestyle choices, and costly forms of health care utilization. J Clin Psychiatry. Dec. 2004;65(12):1660-5. Not eligible level of evidence. [pmid: 15641871].
1421 Frankenburg FR, Zanarini MC. Obesity and obesity-related illnesses in borderline patients. J Personal Disord. Feb. 2006;20(1):71-80. Not eligible level of evidence. [pmid: 16563080].
1422 Franks ME, Lavelle JP, Yokoyama T, et al. Metastatic osteomyelitis after pubovaginal sling using bone anchors. Urology. Aug 1. 2000;56(2):330-1. Case Reports.
1423 Franssen EH, Souren LE, Torossian CL, et al. Utility of developmental reflexes in the differential diagnosis and prognosis of incontinence in Alzheimer's disease. J Geriatr Psychiatry Neurol. Jan. 1997;10(1):22-8. Not eligible outcomes. [pmid: 9100155].
1424 Fransson P, Bergstrom P, Lofroth PO, et al. Prospective evaluation of urinary and intestinal side effects after BeamCath stereotactic dose-escalated radiotherapy of prostate cancer. Radiother Oncol. Jun. 2002;63(3):239-48. Not eligible level of evidence. [pmid: 12142087].
1425 Fransson P, Bergstrom P, Lofroth PO, et al. Five-year prospective patient evaluation of bladder and bowel symptoms after dose-escalated radiotherapy for prostate cancer with the BeamCath technique. Int J Radiat Oncol Biol Phys. Oct 1. 2006;66(2):430-8. Case series. [pmid: 16904846].
1426 Frantz RA, Xakellis GC Jr, Harvey PC, et al. Implementing an incontinence management protocol in long-term care. Clinical outcomes and costs. J Gerontol Nurs. Aug. 2003;29(8):46-53. Case-series.
1427 Frauscher F, Helweg G, Strasser H, et al. Intraurethral ultrasound: diagnostic evaluation of the striated urethral sphincter in incontinent females. Eur Radiol. 1998;8(1):50-3. Not eligible outcomes. [pmid: 9442128].
1428 Freeman EW, Grisso JA, Berlin J, et al. Symptom reports from a cohort of African American and white women in the late reproductive years. Menopause. Jan–Feb. 2001;8(1):33-42. Not eligible level of evidence. [pmid: 11201513].
1429 Freeman R, Hill S, Millard R, et al. Reduced perception of urgency in treatment of overactive bladder with extended-release tolterodine. Obstet Gynecol. Sep. 2003;102(3):605-11. Not eligible exposure. [pmid: 12962951].
1430 Freeman RM, Adekanmi O, Waterfield MR, et al. The effect of cannabis on urge incontinence in patients with multiple sclerosis: a multicentre, randomised placebo-controlled trial (CAMS-LUTS). Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2006;17(6):636-41. Not eligible exposure. [pmid: 16552618].
1431 Freeman SB. Management of perimenopausal symptoms. NAACOGS Clin Issu Perinat Womens Health Nurs. 1991;2(4):429-39. Review. [pmid: 1772730].
1432 Fried GW, Goetz G, Potts-Nulty S, et al. A behavioral approach to the treatment of urinary incontinence in a disabled population. Arch Phys Med Rehabil. Dec. 1995;76(12):1120-4. Case-series. [pmid: 8540787].
1433 Friedman WH, Gallup DG, Burke JJ 2nd, et al. Outcomes of octogenarians and nonagenarians in elective major gynecologic surgery. Am J Obstet Gynecol. Aug. 2006;195(2):547-52. discussion 52–3. Not eligible outcomes. [pmid: 16890555].
1434 Frieri G, Ligas E, Perugini B, et al. Ulcerative colitis: rectal dilations in a patient with refractory diarrhea. Report of a case. Dis Colon Rectum. May. 1995;38(5):545-9. Case- Reports. [pmid: 7736888].
1435 Frigell A, Ottander M, Stenbeck H, et al. Quality of life of patients treated with abdominoperineal resection or anterior resection for rectal carcinoma. Ann Chir Gynaecol. 1990;79(1):26-30. case-series. [pmid: 2357050].
1436 Frisbie JH. Improved bowel care with a polyethylene glycol based bisacadyl suppository. J Spinal Cord Med. Apr. 1997;20(2):227-9. Case-series. [pmid: 9144613].
1437 Fritel X, Pigne A. Anterior repair using Bologna procedure: long-term results on stress urinary continence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(3):176-81. discussion 81. Not eligible level of evidence. [pmid: 12140711].
1438 Fritel X, Zabak K, Pigne A, et al. Predictive value of urethral mobility before suburethral tape procedure for urinary stress incontinence in women. J Urol. Dec. 2002;168(6):2472-5. Case-series. [pmid: 12441943].
1439 Frizelle FA, Gearry RB, Johnston M, et al. Penile and clitoral stimulation for faecal incontinence: external application of a bipolar electrode for patients with faecal incontinence. Colorectal Dis. Jan. 2004;6(1):54-7. Case-series. [pmid: 14692954].
1440 Froeling FM, Deprest JA, Ankum WM, et al. Controlled balloon dilatation for laparoscopic extraperitoneal bladder neck suspension in patients with previous abdominal surgery. J Laparoendosc Adv Surg Tech A. Feb. 2000;10(1):27-30. Case-series. [pmid: 10706299].
1441 Frudinger A, Bartram CI, Halligan S, et al. Examination techniques for endosonography of the anal canal. Abdom Imaging. May–Jun. 1998;23(3):301-3. Not eligible outcomes. [pmid: 9569302].
1442 Frudinger A, Bartram CI, Spencer JA, et al. Perineal examination as a predictor of underlying external anal sphincter damage. Br J Obstet Gynaecol. Sep. 1997;104(9):1009-13. Case-series. [pmid: 9307526].
1443 Frudinger A, Halligan S, Bartram CI, et al. Assessment of the predictive value of a bowel symptom questionnaire in identifying perianal and anal sphincter trauma after vaginal delivery. Dis Colon Rectum. Jun. 2003;46(6):742-7. Not eligible outcomes. [pmid: 12794575].
1444 Fu X, Rezapour M, Wu X, et al. Expression of estrogen receptor-alpha and -beta in anterior vaginal walls of genuine stress incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):276-81. discussion 81. Not eligible outcomes. [pmid: 14530841].
1445 Fujisawa M, Higuchi A, Gotoh A, et al. Outcome of precise vesicourethral anastomosis following retropubic radical prostatectomy using a Foley catheter. Int J Urol. Feb. 1999;6(2):75-7. Not eligible target population. [pmid: 10226811].
1446 Fujita M, Ohno S, Danno K, et al. Two cases of diaper area granuloma of the adult. J Dermatol. Nov. 1991;18(11):671-5. Case-series. [pmid: 1800534].
1447 Fukunaga K, Kimura K, Lawrence JP, et al. Button device for antegrade enema in the treatment of incontinence and constipation. J Pediatr Surg. Aug. 1996;31(8):1038-9. Case-reports. [pmid: 8863228].
1448 Fulcher RA, Maisey SP. Evaluation of dipstick tests and reflectance meter for screening for bacteriuria in elderly patients. Br J Clin Pract. Winter. 1991;45(4):245-6. Not eligible outcomes. [pmid: 1810355].
1449 Fuller MA, Borovicka MC, Jaskiw GE, et al. Clozapine-induced urinary incontinence: incidence and treatment with ephedrine. J Clin Psychiatry. Nov. 1996;57(11):514-8. Not eligible target population. [pmid: 8968299].
1450 Fulmer BR, Bissonette EA, Petroni GR, et al. Prospective assessment of voiding and sexual function after treatment for localized prostate carcinoma: comparison of radical prostatectomy to hormonobrachytherapy with and without external beam radiotherapy. Cancer. Jun 1. 2001;91(11):2046-55. Not eligible level of evidence. [pmid: 11391584].
1451 Fulmer BR, Sakamoto K, Turk TM, et al. Acute and long-term outcomes of radio frequency bladder neck suspension. J Urol. Jan. 2002;167(1):141-5. Not eligible target population. [pmid: 11743293].
1452 Fultz N, Girts T, Kinchen K, et al. Prevalence, management and impact of urinary incontinence in the workplace. Occup Med (Lond). Oct. 2005;55(7):552-7. Not eligible level of evidence. [pmid: 16251372].
1453 Fultz NH, Herzog AR. Measuring urinary incontinence in surveys. Gerontologist. Dec. 1993;33(6):708-13. Comment. [pmid: 8314096].
1454 Fultz NH, Herzog AR. Prevalence of urinary incontinence in middle-aged and older women: a survey-based methodological experiment. J Aging Health. Nov. 2000;12(4):459-69. Not eligible level of evidence. [pmid: 11503727].
1455 Fultz NH, Herzog AR. Self-reported social and emotional impact of urinary incontinence. J Am Geriatr Soc. Jul. 2001;49(7):892-9. Not eligible outcomes. [pmid: 11527480].
1456 Fultz NH, Rahrig Jenkins K, Ostbye T, et al. The impact of own and spouse's urinary incontinence on depressive symptoms. Soc Sci Med. Jun. 2005;60(11):2537-48. Not eligible outcomes. [pmid: 15814179].
1457 Fynes M, Donnelly V, Behan M, et al. Effect of second vaginal delivery on anorectal physiology and faecal continence: a prospective study. Lancet. Sep 18. 1999;354(9183):983-6. Case-series. [pmid: 10501360].
1458 Gadonneix P, Ercoli A, Salet-Lizee D, et al. Laparoscopic sacrocolpopexy with two separate meshes along the anterior and posterior vaginal walls for multicompartment pelvic organ prolapse. J Am Assoc Gynecol Laparosc. Feb. 2004;11(1):29-35. Case-series. [pmid: 15104827].
1459 Gahimer J, Wernicke J, Yalcin I, et al. A retrospective pooled analysis of duloxetine safety in 23,983 subjects. Curr Med Res Opin. Jan. 2007;23(1):175-84. Not eligible target population. [pmid: 17257478].
1460 Gaker DL, Gaker LB, Stewart JF, et al. Radical prostatectomy with preservation of urinary continence. J Urol. Aug. 1996;156(2 Pt 1):445-9. Case-series. [pmid: 8683699].
1461 Gaker DL, Steel BL. Radical prostatectomy with preservation of urinary continence: pathology and long-term results. J Urol. Dec. 2004;172(6 Pt 2):2549-52. Case-series. [pmid: 15538205].
1462 Galandiuk S, Scott NA, Dozois RR, et al. Ileal pouch-anal anastomosis. Reoperation for pouch-related complications. Ann Surg. Oct. 1990;212(4):446-52. discussion 52–4. Not eligible outcomes. [pmid: 2171442]. [pmcid: 1358276].
1463 Galarneau L. Bedside cystometry—a useful diagnostic tool for nurse continence advisors. Perspectives. Spring. 2003;27(1):3-5. Comment. [pmid: 12894655].
1464 Gallagher PV, Mellon JK, Ramsden PD, et al. Tanagho bladder neck reconstruction in the treatment of adult incontinence. J Urol. May. 1995;153(5):1451-4. Case-series. [pmid: 7714963].
1465 Gallentine ML, Cespedes RD. Occult stress urinary incontinence and the effect of vaginal vault prolapse on abdominal leak point pressures. Urology. Jan. 2001;57(1):40-4. Case-series.
1466 Galli S, Simonato A, Bozzola A, et al. Oncologic outcome and continence recovery after laparoscopic radical prostatectomy: 3 years' follow-up in a “second generation center”. Eur Urol. May. 2006;49(5):859-65. Case-series. [pmid: 16519991].
1467 Gallien P, Robineau S, Nicolas B, et al. Vesicourethral dysfunction and urodynamic findings in multiple sclerosis: a study of 149 cases. Arch Phys Med Rehabil. Mar. 1998;79(3):255-7. Not eligible outcomes. [pmid: 9523775].
1468 Gallo M, Staskin DR. Patient satisfaction with a reusable undergarment for urinary incontinence. J Wound Ostomy Continence Nurs. Jul. 1997;24(4):226-36. Not eligible outcomes. [pmid: 9274280].
1469 Gallo ML, Fallon PJ. Evaluation of a pelvic floor treatment plan for patients undergoing radical prostatectomy. Urol Nurs. Mar. 1996;16(1):9-13. Case-series. [pmid: 8826389].
1470 Gallo ML, Hancock R, Davila GW. Clinical experience with a balloon-tipped urethral insert for stress urinary incontinence. J Wound Ostomy Continence Nurs. Jan. 1997;24(1):51-7. no associative hypothesis tested. [pmid: 9204850].
1471 Gallo ML, Staskin DR. Cues to action: pelvic floor muscle exercise compliance in women with stress urinary incontinence. Neurourol Urodyn. 1997;16(3):167-77. Not eligible outcomes. [pmid: 9136139].
1472 Galloway NT, El-Galley RE, Sand PK, et al. Extracorporeal magnetic innervation therapy for stress urinary incontinence. Urology. Jun. 1999;53(6):1108-11. Not eligible target population. [pmid: 10367836].
1473 Galloway NT, El-Galley RE, Sand PK, et al. Update on extracorporeal magnetic innervation (EXMI) therapy for stress urinary incontinence. Urology. Dec 4. 2000;56(6 Suppl 1):82-6. Not eligible target population.
1474 Gambassi G, Landi F, Lapane KL, et al. Predictors of mortality in patients with Alzheimer's disease living in nursing homes. J Neurol Neurosurg Psychiatry. Jul. 1999;67(1):59-65. Not eligible outcomes. [pmid: 10369823]. [pmcid: 1736445].
1475 Gambino J, Cohen AJ, Friedenberg RM. The direction of bladder displacement by adnexal masses. Clin Imaging. Jan–Mar. 1993;17(1):8-11. Case-series. [pmid: 8439853].
1476 Game X, Villers A, Malavaud B, et al. Bladder cancer arising in a spina bifida patient. Urology. Nov. 1999;54(5):923. Case Reports. [pmid: 10754152].
1477 Ganabathi K, Leach GE, Zimmern PE, et al. Experience with the management of urethral diverticulum in 63 women. J Urol. Nov. 1994;152(5 Pt 1):1445-52. Case-series. [pmid: 7933181].
1478 Gandhi S, Abramov Y, Kwon C, et al. TVT versus SPARC: comparison of outcomes for two midurethral tape procedures. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2006;17(2):125-30. Not eligible target population. [pmid: 16079957].
1479 Ganio E, Luc AR, Clerico G, et al. Sacral nerve stimulation for treatment of fecal incontinence: a novel approach for intractable fecal incontinence. Dis Colon Rectum. May. 2001;44(5):619-29. discussion 29–31. Not eligible target population. [pmid: 11357019].
1480 Ganio E, Masin A, Ratto C, et al. Short-term sacral nerve stimulation for functional anorectal and urinary disturbances: results in 40 patients: evaluation of a new option for anorectal functional disorders. Dis Colon Rectum. Sep. 2001;44(9):1261-7. Not eligible target population. [pmid: 11584196].
1481 Ganio E, Ratto C, Masin A, et al. Neuromodulation for fecal incontinence: outcome in 16 patients with definitive implant. The initial Italian Sacral Neurostimulation Group (GINS) experience. Dis Colon Rectum. Jul. 2001;44(7):965-70. Not eligible target population. [pmid: 11496076].
1482 Ganta SB, Chakravarti A, Somani B, et al. Removal of catheter at midnight versus early morning: the patients' perspective. Urol Int. 2005;75(1):26-9. Not eligible exposure. [pmid: 16037704].
1483 Ganz DA, Wenger NS, Roth CP, et al. The effect of a quality improvement initiative on the quality of other aspects of health care: the law of unintended consequences?. Med Care. Jan. 2007;45(1):8-18. Not eligible outcomes. [pmid: 17279017].
1484 Ganz PA, Greendale GA, Petersen L, et al. Managing menopausal symptoms in breast cancer survivors: results of a randomized controlled trial. J Natl Cancer Inst. Jul 5. 2000;92(13):1054-64. Not eligible outcomes. [pmid: 10880548].
1485 Garber SJ, Christmas TJ, Rickards D. Voiding dysfunction due to neurosyphilis. Br J Urol. Jul. 1990;66(1):19-21. Case- Reports. [pmid: 2393795].
1486 Garcea G, Sutton C, Mansoori S, et al. Results following conservative lateral sphincteromy for the treatment of chronic anal fissures. Colorectal Dis. Jul. 2003;5(4):311-4. Case-series. [pmid: 12814407].
1487 Garcia A, Smith M, Freedman M. Vitamin B12 deficiency and incontinence in older people. Can J Urol. Aug. 2000;7(4):1077-80. Not eligible level of evidence. [pmid: 11109078].
1488 Garcia Armengol J, Hinojosa J, Lledo S, et al. Evolutive study of the functional results after restorative proctocolectomy for ulcerative colitis. Rev Esp Enferm Dig. Sep. 1997;89(9):685-98. Case-series. [pmid: 9421555].
1489 Garcia JG, Lam C. Treating urinary incontinence in a head-injured adult. Brain Inj. Apr–Jun. 1990;4(2):203-7. Case- Reports. [pmid: 2331550].
1490 Garcia Montes JM, Caunedo Alvarez A, Herrerias Gutierrez JM. Utility of the endo-rectal ultrasonography with sectorial transducer in the study of rectoanal pathology. Rev Esp Enferm Dig. Aug. 2001;93(8):509-18. Not eligible target population. [pmid: 11692780].
1491 Garcia-Aguilar J, Belmonte C, Wong DW, et al. Cutting seton versus two-stage seton fistulotomy in the surgical management of high anal fistula. Br J Surg. Feb. 1998;85(2):243-5. Case-series. [pmid: 9501826].
1492 Garcia-Aguilar J, Belmonte Montes C, Perez JJ, et al. Incontinence after lateral internal sphincterotomy: anatomic and functional evaluation. Dis Colon Rectum. Apr. 1998;41(4):423-7. Not eligible outcomes. [pmid: 9559625].
1493 Garcia-Aguilar J, Davey CS, Le CT, et al. Patient satisfaction after surgical treatment for fistula-in-ano. Dis Colon Rectum. Sep. 2000;43(9):1206-12. Not eligible outcomes. [pmid: 11005484].
1494 Garcia-Granero E, Sanahuja A, Garcia-Armengol J, et al. Anal endosonographic evaluation after closed lateral subcutaneous sphincterotomy. Dis Colon Rectum. May. 1998;41(5):598-601. Question 4. [pmid: 9593242].
1495 Garcia-Olmo D, Garcia-Arranz M, Garcia LG, et al. Autologous stem cell transplantation for treatment of rectovaginal fistula in perianal Crohn's disease: a new cell-based therapy. Int J Colorectal Dis. Sep. 2003;18(5):451-4. Case- Reports. [pmid: 12756590].
1496 Gardner BG, Zietman AL, Shipley WU, et al. Late normal tissue sequelae in the second decade after high dose radiation therapy with combined photons and conformal protons for locally advanced prostate cancer. J Urol. Jan. 2002;167(1):123-6. Case-series. [pmid: 11743288].
1497 Gardy M, Kozminski M, DeLancey J, et al. Stress incontinence and cystoceles. J Urol. Jun. 1991;145(6):1211-3. Case-series. [pmid: 2033695].
1498 Garely AD, Lucente V, Vapnek J, et al. Solifenacin for overactive bladder with incontinence: symptom bother and health-related quality of life outcomes. Ann Pharmacother. Mar. 2007;41(3):391-8. Not eligible target population. [pmid: 17341526].
1499 Gariballa SE. Potentially treatable causes of poor outcome in acute stroke patients with urinary incontinence. Acta Neurol Scand. May. 2003;107(5):336-40. Not eligible outcomes. [pmid: 12713525].
1500 Garrido R, Lagos N, Lattes K, et al. Gonyautoxin: new treatment for healing acute and chronic anal fissures. Dis Colon Rectum. Feb. 2005;48(2):335-40. discussion 40–3. Not eligible outcomes. [pmid: 15812585].
1501 Gasparini ME, Hinman F Jr, Presti JC Jr, et al. Continence after radical cystoprostatectomy and total bladder replacement: a urodynamic analysis. J Urol. Dec. 1992;148(6):1861-4. Case-series. [pmid: 1433621].
1502 Gateau T, Faramarzi-Roques R, Le Normand L, et al. Clinical and urodynamic repercussions after TVT procedure and how to diminish patient complaints. Eur Urol. Sep. 2003;44(3):372-6. discussion 6. Not eligible target population. [pmid: 12932939].
1503 Gaur C, Mathur A, Agarwal A, et al. Diabetic autonomic neuropathy causing gall bladder dysfunction. J Assoc Physicians India. Jun. 2000;48(6):603-5. Not eligible target population. [pmid: 11273539].
1504 Gauruder-Burmester A, A R. Pregnancy and labor after TVT-plasty. Acta Obstet Gynecol Scand. Mar. 2001;80(3):283-4. Case-reports. [pmid: 11207500].
1505 Gauthier AR Jr, Winters JC. Incontinent ileovesicostomy in the management of neurogenic bladder dysfunction. Neurourol Urodyn. 2003;22(2):142-6. Case-series. [pmid: 12579632].
1506 Gavagan JA, Whiteford MH, Swanstrom LL. Full-thickness intraperitoneal excision by transanal endoscopic microsurgery does not increase short-term complications. Am J Surg. May. 2004;187(5):630-4. Case-series. [pmid: 15135680].
1507 Gavira Iglesias FJ, Caridady Ocerin JM, Perez del Molino Martin PJ, et al. Prevalence and psychosocial impact of urinary incontinence in older people of a Spanish rural population. Journals of Gerontology. Series A: Biological Sciences and Medical Sciences. Apr. 2000;55A(4):M207-14. Not eligible level of evidence.
1508 Gearhart JP, Peppas DS, Jeffs RD. Complete genitourinary reconstruction in female epispadias. J Urol. May. 1993;149(5):1110-3. Case-series. [pmid: 8483224].
1509 Gearhart S, Hull T, Floruta C, et al. Anal manometric parameters: predictors of outcome following anal sphincter repair?. J Gastrointest Surg. Jan. 2005;9(1):115-20. Case-series. [pmid: 15623452].
1510 Gearhart SL, Hull TL, Schroeder T, et al. Sphincter defects are not associated with long-term incontinence following ileal pouch-anal anastomosis. Dis Colon Rectum. Jul. 2005;48(7):1410-5. Case-series. [pmid: 15793633].
1511 Gearhart SL, Pannu HK, Cundiff GW, et al. Perineal descent and levator ani hernia: a dynamic magnetic resonance imaging study. Dis Colon Rectum. Aug. 2004;47(8):1298-304. Not eligible outcomes. [pmid: 15484342].
1512 Geary ES, Dendinger TE, Freiha FS, et al. Nerve sparing radical prostatectomy: a different view. J Urol. Jul. 1995;154(1):145-9. Case-series. [pmid: 7776409].
1513 Gee AS, Durdey P. Urge incontinence of faeces is a marker of severe external anal sphincter dysfunction. Br J Surg. Sep. 1995;82(9):1179-82. Not eligible outcomes. [pmid: 7551990].
1514 Gee AS, Durdey P. Preoperative increase in neuromuscular jitter and outcome following surgery for faecal incontinence. Br J Surg. Sep. 1997;84(9):1265-8. Not eligible exposure. [pmid: 9313710].
1515 Gee AS, Mills A, Durdey P. What is the relationship between perineal descent and anal mucosal electrosensitivity?. Dis Colon Rectum. Apr. 1995;38(4):419-23. Not eligible outcomes. [pmid: 7720452].
1516 Geerdes BP, Heineman E, Konsten J, et al. Dynamic graciloplasty. Complications and management. Dis Colon Rectum. Aug. 1996;39(8):912-7. Not eligible target population. [pmid: 8756848].
1517 Geerdes BP, Kurvers HA, Konsten J, et al. Assessment of ischaemia of the distal part of the gracilis muscle during transposition for anal dynamic graciloplasty. Br J Surg. Aug. 1997;84(8):1127-9. Not eligible target population. [pmid: 9278660].
1518 Geirsson G, Fall M. Maximal functional electrical stimulation in routine practice. Neurourol Urodyn. 1997;16(6):559-65. Case-series. [pmid: 9353805].
1519 Geirsson G, Fall M, Lindstrom S. The ice-water test—a simple and valuable supplement to routine cystometry. Br J Urol. Jun. 1993;71(6):681-5. Not eligible outcomes. [pmid: 8343894].
1520 Gelber DA, Good DC, Laven LJ, et al. Causes of urinary incontinence after acute hemispheric stroke. Stroke. Mar. 1993;24(3):378-82. Case-series. [pmid: 8446973].
1521 Gelet A, Meunier P, Platet RL, et al. Treatment of dual urinary and fecal incontinence by implantation of two AMS 800 artificial sphincters. Case report. Eur Urol. 1997;31(1):115-7. discussion 7–8. Case-reports. [pmid: 9032547].
1522 Gelet A, Sanseverino R, Salas M, et al. The AS 800 urinary sphincter in renal transplantation. Br J Urol. Nov. 1990;66(5):549-50. Case-reports. [pmid: 2249132].
1523 Gelister JS, Woodhouse CR. Role of continent suprapubic diversion in pelvic cancer. Br J Urol. Oct. 1991;68(4):376-9. Case-series. [pmid: 1834296].
1524 Gemlo BT, Belmonte C, Wiltz O, et al. Functional assessment of ileal pouch-anal anastomotic techniques. Am J Surg. Jan. 1995;169(1):137-41. discussion 41–2. Case-series. [pmid: 7817983].
1525 George BD, Williams NS, Patel J, et al. Physiological and histochemical adaptation of the electrically stimulated gracilis muscle to neoanal sphincter function. Br J Surg. Oct. 1993;80(10):1342-6. Case-series. [pmid: 8242319].
1526 George VK, Russell GL, Shutt A, et al. Clam ileocystoplasty. Br J Urol. Nov. 1991;68(5):487-9. Case-series. [pmid: 1747723].
1527 Georgiou M, Shehata HA, Chaliha C, et al. Fasciitis: a rare complication of Burch colposuspension. Bjog. Feb. 2001;108(2):227-9. Case Reports. [pmid: 11236127].
1528 Gerber SD. They don't all live happily ever after. Nursing. Mar. 1991;21(3):136. Case Reports. [pmid: 2002921].
1529 Gerharz EW, Kohl UN, Weingartner K, et al. Experience with the Mainz modification of ureterosigmoidostomy. Br J Surg. Nov. 1998;85(11):1512-6. Case-series. [pmid: 9823913].
1530 Gerharz EW, Vik V, Webb G, et al. The value of the MACE (Malone antegrade colonic enema) procedure in adult patients. J Am Coll Surg. Dec. 1997;185(6):544-7. Case-series. [pmid: 9404877].
1531 Gerharz EW, Vik V, Webb G, et al. The in situ appendix in the Malone antegrade continence enema procedure for faecal incontinence. Br J Urol. Jun. 1997;79(6):985-6. Case-reports. [pmid: 9202571].
1532 Gerrard ER Jr, Lloyd LK, Kubricht WS, et al. Transvaginal ultrasound for the diagnosis of urethral diverticulum. J Urol. Apr. 2003;169(4):1395-7. Not eligible outcomes. [pmid: 12629370].
1533 Gerstenbluth RE, Goldman HB. Simultaneous urethral erosion of tension-free vaginal tape and woven polyester pubovaginal sling. J Urol. Aug. 2003;170(2 Pt 1):525-6. Case Reports. [pmid: 12853819].
1534 Gervaz P, Rotholtz N, Wexner SD, et al. Colonic J-pouch function in rectal cancer patients: impact of adjuvant chemoradiotherapy. Dis Colon Rectum. Nov. 2001;44(11):1667-75. Case-series. [pmid: 11711740].
1535 Ghali WA, Freund KM, Boss RD, et al. Menopausal hormone therapy: physician awareness of patient attitudes. Am J Med. Jul. 1997;103(1):3-10. Not eligible outcomes. [pmid: 9236479].
1536 Ghei M, Malone-Lee J. Using the circumstances of symptom experience to assess the severity of urgency in the overactive bladder. J Urol. Sep. 2005;174(3):972-6. Not eligible outcomes. [pmid: 16094017].
1537 Ghei M, Maraj BH, Miller R, et al. Effects of botulinum toxin B on refractory detrusor overactivity: a randomized, double-blind, placebo controlled, crossover trial. J Urol. Nov. 2005;174(5):1873-7. discussion 7. Not eligible exposure. [pmid: 16217327].
1538 Ghei M, Miller R, Malone-Lee J. Case series data to encourage randomized trials of bladder retraining compared to antimuscarinic agents. J Urol. Apr. 2006;175(4):1411-5. discussion 5–6. Not eligible target population. [pmid: 16516010].
1539 Ghezzi F, Cromi A, Raio L, et al. Influence of the type of anesthesia and hydrodissection on the complication rate after tension-free vaginal tape procedure. Eur J Obstet Gynecol Reprod Biol. Jan 10. 2005;118(1):96-100. Not eligible exposure. [pmid: 15596281].
1540 Ghezzi F, Franchi M, Buttarelli M, et al. The use of suction drains at burch colposuspension and postoperative infectious morbidity. Arch Gynecol Obstet. Apr. 2003;268(1):41-4. Not eligible outcomes. [pmid: 12673474].
1541 Ghezzi F, Serati M, Cromi A, et al. Tension-free vaginal tape for the treatment of urodynamic stress incontinence with intrinsic sphincteric deficiency. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):335-9. Case-series. [pmid: 16211315].
1542 Ghoniem GM. The recalcitrant overactive bladder patient. Geriatrics. May. 2002;57(Suppl 1):23-9. Case-reports. [pmid: 12040600].
1543 Ghoniem GM, Van Leeuwen JS, Elser DM, et al. A randomized controlled trial of duloxetine alone, pelvic floor muscle training alone, combined treatment and no active treatment in women with stress urinary incontinence. J Urol. May. 2005;173(5):1647-53. Not eligible exposure. [pmid: 15821528].
1544 Ghoniem GM, Walters F, Lewis V. The value of the vaginal pack test in large cystoceles. J Urol. Sep. 1994;152(3):931-4. Not eligible outcomes. [pmid: 8051758].
1545 Ghosh T, Banfield PJ, Klazinga DA. An unusual complication of tension-free vaginal tape procedure: recurrent anterior vaginal wall abscess and sinus formation. J Obstet Gynaecol. Aug. 2004;24(5):590-1. Case Reports. [pmid: 15369957].
1546 Ghosh TS, Kwawukume EY. A new method of achieving total continence in vesico-urethro-vaginal fistula (circumferential fistula) with total urethral destruction—surgical technique. West Afr J Med. Jul–Sep. 1993;12(3):141-3. Case-series. [pmid: 8312209].
1547 Giacalone PL, Laffargue F, Daures JP, et al. The Bologna bladder neck suspension procedure for treatment of stress urinary incontinence associated with cystocele. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(6):370-8. Case-series. [pmid: 9891958].
1548 Giamundo P, Welber A, Weiss EG, et al. The procon incontinence device: a new nonsurgical approach to preventing episodes of fecal incontinence. Am J Gastroenterol. Sep. 2002;97(9):2328-32. Case-series. [pmid: 12358252].
1549 Giannantoni A, Mearini E, Di Stasi SM, et al. Assessment of bladder and urethral sphincter function before and after radical retropubic prostatectomy. J Urol. Apr. 2004;171(4):1563-6. Case-series. [pmid: 15017221].
1550 Giannitsas K, Perimenis P, Athanasopoulos A, et al. Comparison of the efficacy of tolterodine and oxybutynin in different urodynamic severity grades of idiopathic detrusor overactivity. Eur Urol. Dec. 2004;46(6):776-82. discussion 82–3. Not eligible exposure. [pmid: 15548447].
1551 Gibbons G. Assessing and managing incontinence in women. Community Nurse. Jun. 1996;2(5):34-6. Case Reports. [pmid: 9445729].
1552 Gibbs DH, Hooks VH 3rd. Overlapping sphincteroplasty for acquired anal incontinence. South Med J. Dec. 1993;86(12):1376-80. Case-series. [pmid: 8272915].
1553 Giberti C, Rovida S. Transvaginal bone-anchored synthetic sling for the treatment of stress urinary incontinence: an outcomes analysis. Urology. Dec 20. 2000;56(6):956-61. Case-series. [pmid: 11113740].
1554 Gilbert R, Glen M. Implementing an NHS continence service for nursing home residents. Prof Nurse. Nov. 2004;20(3):35-7. Not eligible exposure. [pmid: 15552438].
1555 Giles DL, Davila GW. Suprapubic-vaginocutaneous fistula 18 years after a bladder-neck suspension. Obstet Gynecol. May. 2005;105(5 Pt 2):1193-5. Case Reports. [pmid: 15863578].
1556 Giles LG, Yamada S. An unusual cause of incontinence. Aust Fam Physician. Aug. 2001;30(8):767-9. Case report. [pmid: 11681149].
1557 Gilja I. Tansvaginal needle suspension operation: the way we do it. Clinical and urodynamic study: long-term results. Eur Urol. Mar. 2000;37(3):325-30. Case-series. [pmid: 10720860].
1558 Gilja I, Kovacic M, Radej M, et al. The sigmoidorectal pouch (Mainz pouch II). Eur Urol. 1996;29(2):210-5. No associative hypothesis tested. [pmid: 8647149].
1559 Gilja I, Sarac S, Radej M. A modified Raz bladder neck suspension operation (transvaginal Burch). J Urol. May. 1995;153(5):1455-7. Case-series. [pmid: 7714964].
1560 Gill EJ, Elser DM, Bonidie MJ, et al. The routine use of cystoscopy with the Burch procedure. Am J Obstet Gynecol. Aug. 2001;185(2):345-8. Not eligible outcomes. [pmid: 11518889].
1561 Gill EJ, Nichols CM. Cystoscopic confirmation of inadvertent ureteral catheterization during cystometry. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(4):266-7. Case Reports. [pmid: 12189434].
1562 Gill SS, Mamdani M, Naglie G, et al. A prescribing cascade involving cholinesterase inhibitors and anticholinergic drugs. Arch Intern Med. Apr 11. 2005;165(7):808-13. Not eligible exposure. [pmid: 15824303].
1563 Gillatt DA, Feneley RC. Magnetic resonance imaging in the identification of an otherwise undetectable upper pole moiety. Br J Urol. Jul. 1993;72(1):122-3. Case report. [pmid: 8054016].
1564 Gilleran JP, Lemack GE, Zimmern PE. Reduction of moderate-to-large cystocele during urodynamic evaluation using a vaginal gauze pack: 8-year experience. BJU Int. Feb. 2006;97(2):292-5. Not eligible exposure. [pmid: 16430632].
1565 Gillon G, Engelstein D, Servadio C. Risk factors and their effect on the results of Burch colposuspension for urinary stress incontinence. Isr J Med Sci. Jun. 1992;28(6):354-6. Case-series. [pmid: 1607271].
1566 Gil-Nagel A, Gapany S, Blesi K, et al. Incontinence during treatment with gabapentin. Neurology. May. 1997;48(5):1467-8. Case- Reports. [pmid: 9153498].
1567 Gimbel H, Zobbe V, Andersen BM, et al. Total versus subtotal hysterectomy: an observational study with one-year follow-up. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):64-7. Not eligible level of evidence. [pmid: 15730368].
1568 Ginsberg D, Rovner E, Raz S. Continence mechanism based on a modified ileocecal valve. Tech Urol. Sep. 2000;6(3):167-71. Case-series. [pmid: 10963479].
1569 Ginsberg DA, Rovner ES, Raz S. Posthysterectomy vaginal cuff fistula: diagnosis and management of an unusual cause of “incontinence”. Urology. Jul. 1998;52(1):61-4. discussion 4–5. Case-reports. [pmid: 9671872].
1570 Girao MJ, Jarmy-Di Bella ZI, Sartori MG, et al. Doppler velocimetry parameters of periurethral vessels in postmenopausal incontinent women receiving estrogen replacement. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(4):241-6. Case-series. [pmid: 11569652].
1571 Girgin C, Oder M, Sahin MO, et al. Erection- and ejaculation-preserving cystectomy with orthotopic urinary diversion: is it feasible?. J Androl. Mar–Apr. 2006;27(2):263-7. Case-series. [pmid: 16304209].
1572 Giri SK, Hickey JP, Sil D, et al. The long-term results of pubovaginal sling surgery using acellular cross-linked porcine dermis in the treatment of urodynamic stress incontinence. J Urol. May. 2006;175(5):1788-92. discussion 93. Case-series. [pmid: 16600762].
1573 Girman CJ, Chandler JM, Zimmerman SI, et al. Prediction of fracture in nursing home residents. J Am Geriatr Soc. Aug. 2002;50(8):1341-7. Not eligible outcomes. [pmid: 12164989].
1574 Gjessing H, Backe B, Sahlin Y. Third degree obstetric tears; outcome after primary repair. Acta Obstet Gynecol Scand. Aug. 1998;77(7):736-40. Case-series. [pmid: 9740521].
1575 Gladman JR, Harwood DM, Barer DH. Predicting the outcome of acute stroke: prospective evaluation of five multivariate models and comparison with simple methods. J Neurol Neurosurg Psychiatry. May. 1992;55(5):347-51. Not eligible outcomes. [pmid: 1602306]. [pmcid: 489073].
1576 Gladman MA, Dvorkin LS, Lunniss PJ, et al. Rectal hyposensitivity: a disorder of the rectal wall or the afferent pathway? An assessment using the barostat. Am J Gastroenterol. Jan. 2005;100(1):106-14. Not eligible outcomes. [pmid: 15654789].
1577 Gladman MA, Scott SM, Chan CL, et al. Rectal hyposensitivity: prevalence and clinical impact in patients with intractable constipation and fecal incontinence. Dis Colon Rectum. Feb. 2003;46(2):238-46. Not eligible outcomes. [pmid: 12576898].
1578 Gladman MA, Scott SM, Williams NS, et al. Clinical and physiological findings, and possible aetiological factors of rectal hyposensitivity. Br J Surg. Jul. 2003;90(7):860-6. Not eligible exposure. [pmid: 12854114].
1579 Glasgow SC, Birnbaum EH, Kodner IJ, et al. Preoperative anal manometry predicts continence after perineal proctectomy for rectal prolapse. Dis Colon Rectum. Jul. 2006;49(7):1052-8. Not eligible outcomes. [pmid: 16649117].
1580 Glavind K. Use of a vaginal sponge during aerobic exercises in patients with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(6):351-3. No associative hypothesis tested. [pmid: 9609334].
1581 Glavind K. Conservative treatment of stress incontinence with Geisha balls. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(4):223-4. discussion 4–5. Case-series. [pmid: 11569648].
1582 Glavind K, Bjork J, Nohr M, et al. A prospective study on whether a tension-free urethropexy procedure affects the residual urine and flow up to 4 years after the operation. Acta Obstet Gynecol Scand. 2006;85(8):982-5. Case-series. [pmid: 16862479].
1583 Glavind K, Glavind E. Treatment of prolonged voiding dysfunction after tension-free vaginal tape procedure. Acta Obstet Gynecol Scand. 2007;86(3):357-60. Case-series. [pmid: 17364313].
1584 Glavind K, Kempf L. Colpectomy or Le Fort colpocleisis—a good option in selected elderly patients. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):48-51. discussion Not eligible target population. [pmid: 15322743].
1585 Glavind K, Laursen B, Jaquet A. Efficacy of biofeedback in the treatment of urinary stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(3):151-3. Case-series. [pmid: 9745974].
1586 Glavind K, Sander P. Erosion, defective healing and extrusion after tension-free urethropexy for the treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):179-82. Not eligible outcomes. [pmid: 15167997].
1587 Glavind K, Tetsche MS. Sexual function in women before and after suburethral sling operation for stress urinary incontinence: a retrospective questionnaire study. Acta Obstet Gynecol Scand. Oct. 2004;83(10):965-8. Not eligible outcomes. [pmid: 15453895].
1588 Gleason DM, Susset J, White C, et al. Evaluation of a new once-daily formulation of oxbutynin for the treatment of urinary urge incontinence. Ditropan XL Study Group. Urology. Sep. 1999;54(3):420-3. Not eligible target population. [pmid: 10475346].
1589 Glenn J. Restorative Nursing Bladder Training program: recommending a strategy. Rehabil Nurs. Jan–Feb. 2003;28(1):15-22. Case-series. [pmid: 12567817].
1590 Glia A, Gylin M, Akerlund JE, et al. Biofeedback training in patients with fecal incontinence. Dis Colon Rectum. Mar. 1998;41(3):359-64. Case-series. [pmid: 9514433].
1591 Glickman S, Kamm MA. Bowel dysfunction in spinal-cord-injury patients. Lancet. Jun 15. 1996;347(9016):1651-3. Case-series. [pmid: 8642958].
1592 Gnanadesigan N, Saliba D, Roth CP, et al. The quality of care provided to vulnerable older community-based patients with urinary incontinence. Journal of the American Medical Directors Association. May–Jun. 2004;5(3):141-6. Not eligible level of evidence. [pmid: 15115573].
1593 Gnanapragasam VJ, Kumar V, Langton D, et al. Outcome of transurethral prostatectomy for the palliative management of lower urinary tract symptoms in men with prostate cancer. Int J Urol. Jun. 2006;13(6):711-5. Case-series. [pmid: 16834648].
1594 Gnessin E, Livne PM, Baniel J, et al. Continence and quality of life assessment after artificial urinary sphincter implantation. Isr Med Assoc J. Oct. 2004;6(10):592-4. Case-series. [pmid: 15473584].
1595 Godfrey K. Incontinence in ethnic groups. Community Nurse. Jun. 1997;3(5):42. Comment. [pmid: 9451153].
1596 Goei R. Anorectal function in patients with defecation disorders and asymptomatic subjects: evaluation with defecography. Radiology. Jan. 1990;174(1):121-3. Not eligible outcomes. [pmid: 2294537].
1597 Goel A, Seth A, Kumar R. Autocystectomy following extensive genitourinary tuberculosis: presentation and management. Int Urol Nephrol. 2002;34(3):325-7. Case-reports. [pmid: 12899222].
1598 Goel MC, Roberts JG. Dynamic rectus abdominis tendon colposuspension for female stress urinary incontinence: a new procedure and its follow-up. Urol Int. 2003;71(1):45-50. Case-series. [pmid: 12845260].
1599 Goepel C, Hefler L, Methfessel HD, et al. Periurethral connective tissue status of postmenopausal women with genital prolapse with and without stress incontinence. Acta Obstet Gynecol Scand. Jul. 2003;82(7):659-64. Not eligible outcomes. [pmid: 12790849].
1600 Goepel M, Hoffmann JA, Piro M, et al. Prevalence and physician awareness of symptoms of urinary bladder dysfunction. Eur Urol. Mar. 2002;41(3):234-9. Not eligible outcomes. [pmid: 12180221].
1601 Goepel M, Sperling H, Stohrer M, et al. Management of neurogenic fecal incontinence in myelodysplastic children by a modified continent appendiceal stoma and antegrade colonic enema. Urology. May. 1997;49(5):758-61. Not eligible target population. [pmid: 9145984].
1602 Goere D, Benoist S, Penna C, et al. H-pouch: new isoperistaltic colonic pouch for coloanal anastomosis after rectal resection for cancer: a pilot study. Dis Colon Rectum. Oct. 2004;47(10):1740-4. Case-series. [pmid: 15540309].
1603 Goes RN, Simons AJ, Beart RW Jr. Level of highest mean resting pressure segment in the anal canal. A quantitative assessment of anal sphincter function. Dis Colon Rectum. Mar. 1996;39(3):289-93. Not eligible outcomes. [pmid: 8603550].
1604 Goes RN, Simons AJ, Masri L, et al. Gradient of pressure and time between proximal anal canal and high-pressure zone during internal anal sphincter relaxation. Its role in the fecal continence mechanism. Dis Colon Rectum. Oct. 1995;38(10):1043-6. Not eligible outcomes. [pmid: 7555417].
1605 Goffeng AR, Andersch B, Andersson M, et al. Objective methods cannot predict anal incontinence after primary repair of extensive anal tears. Acta Obstet Gynecol Scand. Apr. 1998;77(4):439-43. Case-series. [pmid: 9598955].
1606 Gofrit ON, Landau EH, Shapiro A, et al. The Stamey procedure for stress incontinence: long-term results. Eur Urol. Oct. 1998;34(4):339-43. Case-series. [pmid: 9748682].
1607 Goke M, Donner K, Ewe K, et al. Intraindividual variability of anorectal manometry parameters. Z Gastroenterol. Apr. 1992;30(4):243-6. Not eligible outcomes. [pmid: 1604907].
1608 Gold DM, Bartram CI, Halligan S, et al. Three-dimensional endoanal sonography in assessing anal canal injury. Br J Surg. Mar. 1999;86(3):365-70. Not eligible outcomes. [pmid: 10201780].
1609 Gold MF. Restoring dignity. Provider 1992 Apr; 18(4):16–8, 20, 2–4. Comment
1610 Gold MF. Breaking through incontinence. Provider 1995 Jul; 21(7):70–2, 4, 6. Comment
1611 Goldberg KB, Ellis DW. Anoxic encephalopathy: a neurobehavioural study in rehabilitation. Brain Inj. Oct. 1997;11(10):743-50. Case Reports. [pmid: 9354250].
1612 Goldberg RP, Koduri S, Lobel RW, et al. Protective effect of suburethral slings on postoperative cystocele recurrence after reconstructive pelvic operation. Am J Obstet Gynecol. Dec. 2001;185(6):1307-12. discussion 12–3. Not eligible outcomes. [pmid: 11744901].
1613 Goldberg RP, Sand PK, Beck H. Early-stage ovarian carcinoma presenting with irritative voiding symptoms and urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(5):342-4. Not eligible outcomes. [pmid: 11716003].
1614 Goldenberg I, Shupak A, Shoshani O. Oxy-helium treatment for refractory neurological decompression sickness: a case report. Aviat Space Environ Med. Jan. 1996;67(1):57-60. Case- Reports. [pmid: 8929204].
1615 Goldstein M, Hawthorne ME, Engeberg S, et al. Urinary incontinence. Why people do not seek help. J Gerontol Nurs. Apr. 1992;18(4):15-20. Not eligible outcomes.
1616 Goldstein SR, Neven P, Zhou L, et al. Raloxifene effect on frequency of surgery for pelvic floor relaxation. Obstet Gynecol. Jul. 2001;98(1):91-6. Not eligible outcomes. [pmid: 11430963].
1617 Goldwasser B, Ben-Chaim J, Golomb J, et al. Bladder neck closure with an Indiana stoma outlet as a technique for continent vesicostomy. Surg Gynecol Obstet. Nov. 1993;177(5):448-50. Case Reports. [pmid: 8211594].
1618 Golimbu M, al-Askari S, Morales P. Transpubic approach for lower urinary tract surgery: a 15-year experience. J Urol. Jan. 1990;143(1):72-6. Not eligible level of evidence. [pmid: 2294267].
1619 Golomb J, Ben-Chaim J, Goldwasser B, et al. Conservative treatment of a vesicocervical fistula resulting from Shirodkar cervical cerclage. J Urol. Apr. 1993;149(4):833-4. Case-reports. [pmid: 8455253].
1620 Golomb J, Groutz A, Mor Y, et al. Management of urethral erosion caused by a pubovaginal fascial sling. Urology. Jan. 2001;57(1):159-60. Case- Reports. [pmid: 11164166].
1621 Golub RW, Wise WE Jr, Kerner BA, et al. Endorectal mucosal advancement flap: the preferred method for complex cryptoglandular fistula-in-ano. J Gastrointest Surg. Sep–Oct. 1997;1(5):487-91. Not eligible level of evidence. [pmid: 17061335].
1622 Goluboff ET, Chang DT, Olsson CA, et al. Urodynamics and the etiology of post-prostatectomy urinary incontinence: the initial Columbia experience. J Urol. Mar. 1995;153(3 Pt 2):1034-7. Case-series. [pmid: 7853552].
1623 Gomes CM, Broderick GA, Sanchez-Ortiz RF, et al. Artificial urinary sphincter for post-prostatectomy incontinence: impact of prior collagen injection on cost and clinical outcome. J Urol. Jan. 2000;163(1):87-90. Case-series. [pmid: 10604321].
1624 Gomes CM, Trigo-Rocha F, Arap MA, et al. Schistosomal myelopathy: urologic manifestations and urodynamic findings. Urology. Feb. 2002;59(2):195-200. Case-series. [pmid: 11834384].
1625 Gomez-Lobo V, Burgansky A, Kim-Schluger L, et al. Gynecologic symptoms and sexual function before and after liver transplantation. J Reprod Med. Jun. 2006;51(6):457-62. Not eligible level of evidence. [pmid: 16846082].
1626 Gomha MA, Boone TB. Artificial urinary sphincter for post-prostatectomy incontinence in men who had prior radiotherapy: a risk and outcome analysis. J Urol. Feb. 2002;167(2 Pt 1):591-6. Case-series. [pmid: 11792924].
1627 Gomha MA, Boone TB. Voiding patterns in patients with post-prostatectomy incontinence: urodynamic and demographic analysis. J Urol. May. 2003;169(5):1766-9. Case-series. [pmid: 12686829].
1628 Gonzalez R, Buson H, Reid C, et al. Seromuscular colocystoplasty lined with urothelium: experience with 16 patients. Urology. Jan. 1995;45(1):124-9. Case-series. [pmid: 7817464].
1629 Goode PS. Behavioral and drug therapy for urinary incontinence. Urology. Mar. 2004;63(3 Suppl 1):58-64. Not eligible exposure. [pmid: 15013654].
1630 Goode PS, Locher JL, Bryant RL, et al. Measurement of postvoid residual urine with portable transabdominal bladder ultrasound scanner and urethral catheterization. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(5):296-300. Not eligible outcomes. [pmid: 11052565].
1631 Goodwin TM, Banks E, Millar LK, et al. Catastrophic shoulder dystocia and emergency symphysiotomy. Am J Obstet Gynecol. Aug. 1997;177(2):463-4. Case Reports. [pmid: 9290471].
1632 Gordon D, Gold R, Pauzner D, et al. Tension-free vaginal tape in the elderly: is it a safe procedure?. Urology. Mar. 2005;65(3):479-82. Not eligible target population. [pmid: 15780359].
1633 Gordon D, Gold RS, Pauzner D, et al. Combined genitourinary prolapse repair and prophylactic tension-free vaginal tape in women with severe prolapse and occult stress urinary incontinence: preliminary results. Urology. Oct. 2001;58(4):547-50. Not eligible target population. [pmid: 11597536].
1634 Gordon D, Groutz A, Ascher-Landsberg J, et al. Double-blind, placebo-controlled study of magnesium hydroxide for treatment of sensory urgency and detrusor instability: preliminary results. Br J Obstet Gynaecol. Jun. 1998;105(6):667-9. Not eligible exposure. [pmid: 9647159].
1635 Gordon D, Groutz A, Sinai T, et al. Sexual function in women attending a urogynecology clinic. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):325-8. Not eligible outcomes. [pmid: 10543342].
1636 Gordon D, Groutz A, Wolman I, et al. Development of postoperative urinary stress incontinence in clinically continent patients undergoing prophylactic Kelly plication during genitourinary prolapse repair. Neurourol Urodyn. 1999;18(3):193-7. discussion 7–8. Not eligible target population. [pmid: 10338439].
1637 Gorman R. Expert system for management of urinary incontinence in women. Proc Annu Symp Comput Appl Med Care 1995:527–31. Not eligible outcomes
1638 Gormley EA, Griffiths DJ, McCracken PN, et al. Polypharmacy and its effect on urinary incontinence in a geriatric population. Br J Urol. Mar. 1993;71(3):265-9. Not eligible level of evidence. [pmid: 8097424].
1639 Gormley EA, Griffiths DJ, McCracken PN, et al. Effect of transurethral resection of the prostate on detrusor instability and urge incontinence in elderly males. Neurourol Urodyn. 1993;12(5):445-53. Case-series. [pmid: 7504554].
1640 Gorton E, Stanton S, Monga A, et al. Periurethral collagen injection: a long-term follow-up study. BJU Int. Dec. 1999;84(9):966-71. Not eligible target population. [pmid: 10571621].
1641 Gosselink MP, Darby M, Zimmerman DD, et al. Long-term follow-up of retrograde colonic irrigation for defaecation disturbances. Colorectal Dis. Jan. 2005;7(1):65-9. Not eligible target population. [pmid: 15606588].
1642 Gosselink MP, West RL, Kuipers EJ, et al. Integrity of the anal sphincters after pouch-anal anastomosis: evaluation with three-dimensional endoanal ultrasonography. Dis Colon Rectum. Sep. 2005;48(9):1728-35. Case-series. [pmid: 15981069].
1643 Gotoh M, Mizutani K, Furukawa T, et al. Quality of micturition in male patients with orthotopic neobladder replacement. World J Urol. Dec. 2000;18(6):411-6. Case-series. [pmid: 11204260].
1644 Goudet P, Roy P, Arveux I, et al. Population-based study of the treatment and prognosis of carcinoma of the rectum. Br J Surg. Nov. 1997;84(11):1546-50. Not eligible outcomes. [pmid: 9393276].
1645 Gough M, McDermott EW, Lyons B, et al. Perforation of bladder carcinoma presenting as acute abdomen. Br J Urol. May. 1992;69(5):541-2. Case Reports.
1646 Gousse AE, Madjar S, Lambert MM, et al. Artificial urinary sphincter for post-radical prostatectomy urinary incontinence: long-term subjective results. J Urol. Nov. 2001;166(5):1755-8. Case-series. [pmid: 11586217].
1647 Gousse AE, Safir MH, Cortina G, et al. Tubulovillous adenoma in the cecal segment after cecocystoplasty. J Urol. Aug. 1998;160(2):490-1. Case Reports. [pmid: 9679906].
1648 Govier FE, Gibbons RP, Correa RJ, et al. Pubovaginal slings using fascia lata for the treatment of intrinsic sphincter deficiency. J Urol. Jan. 1997;157(1):117-21. Not eligible target population. [pmid: 8976230].
1649 Govier FE, Kobashi KC, Kuznetsov DD, et al. Complications of transvaginal silicone-coated polyester synthetic mesh sling. Urology. Oct. 2005;66(4):741-5. Not eligible target population. [pmid: 16230128].
1650 Govier FE, Litwiller S, Nitti V, et al. Percutaneous afferent neuromodulation for the refractory overactive bladder: results of a multicenter study. J Urol. Apr. 2001;165(4):1193-8. Not eligible target population. [pmid: 11257669].
1651 Govier FE, Pritchett TR, Kornman JD. Correlation of the cystoscopic appearance and functional integrity of the female urethral sphincteric mechanism. Urology. Aug. 1994;44(2):250-3. Not eligible outcomes. [pmid: 8048201].
1652 Graefen M, Hammerer P, Michl U, et al. Incidence of positive surgical margins after biopsy-selected nerve-sparing radical prostatectomy. Urology. Mar. 1998;51(3):437-42. Not eligible outcomes. [pmid: 9510349].
1653 Graf W, Ekstrom K, Glimelius B, et al. A pilot study of factors influencing bowel function after colorectal anastomosis. Dis Colon Rectum. Jul. 1996;39(7):744-9. Case-series. [pmid: 8674365].
1654 Graf W, Pahlman L, Ejerblad S. Functional results after seton treatment of high transsphincteric anal fistulas. Eur J Surg. Apr. 1995;161(4):289-91. Case-series. [pmid: 7612773].
1655 Graham CA, Mallett VT. Race as a predictor of urinary incontinence and pelvic organ prolapse. Am J Obstet Gynecol. Jul. 2001;185(1):116-20. Not eligible target population. [pmid: 11483914].
1656 Graham JM, Stresing HA. A modified cystourethropexy in the management of incontinence and dyspareunia. J S C Med Assoc. Nov. 1990;86(11):578-82. [pmid: 2270049].
1657 Graham RA, Atkins MB, Karp DD, et al. Local excision of rectal carcinoma. Early results with combined chemoradiation therapy using 5-fluorouracil and leucovorin. Dis Colon Rectum. Apr. 1994;37(4):308-12. Case-series. [pmid: 8168408].
1658 Gray M, McClain R, Peruggia M, et al. A model for predicting motor urge urinary incontinence. Nurs Res. Mar–Apr. 2001;50(2):116-22. Not eligible outcomes. [pmid: 11302291].
1659 Gray M, Rayome R, Anson C. Incontinence and clean intermittent catheterization following spinal cord injury. Clin Nurs Res. Feb. 1995;4(1):6-18. discussion 9–21. Case-series. [pmid: 7703877].
1660 Gray R, Stern G, Malone-Lee J. Lower urinary tract dysfunction in Parkinson's disease: changes relate to age and not disease. Age Ageing. Nov. 1995;24(6):499-504. Not eligible level of evidence. [pmid: 8588540].
1661 Graziotti P, Giusti G, Seveso M, et al. Retropubic nerve and seminal sparing radical prostatectomy for recurrent bladder neck-prostatic urethra strictures. Arch Ital Urol Androl. Dec. 2005;77(4):181-4. Case-series. [pmid: 16444927].
1662 Grdal M, Tekin A, Erdoan K, et al. Endoscopic silicone injection for female stress urinary incontinence due to intrinsic sphincter deficiency: impact of coexisting urethral mobility on treatment outcome. Urology. Dec. 2002;60(6):1016-9. Case-series. [pmid: 12475660].
1663 Green JP, Smoker I, Ho MT, et al. Urinary incontinence in subacute care—a retrospective analysis of clinical outcomes and costs. Med J Aust. Jun 2. 2003;178(11):550-3. Not eligible outcomes. [pmid: 12765502].
1664 Green N, Treible D, Wallack H. Prostate cancer: post-irradiation incontinence. J Urol. Aug. 1990;144(2 Pt 1):307-9. Case series. [pmid: 2115597].
1665 Greenberger M, Steiner MS. The University of Tennessee experience with the Indigo 830e laser device for the minimally invasive treatment of benign prostatic hyperplasia: interim analysis. World J Urol. 1998;16(6):386-91. Case-series. [pmid: 9870285].
1666 Greendale GA, Petersen L, Zibecchi L, et al. Factors related to sexual function in postmenopausal women with a history of breast cancer. Menopause. Summer. 2001;8(2):111-9. Not eligible outcomes. [pmid: 11256871].
1667 Greer DS. Incontinence in the elderly. R I Med. Aug. 1994;77(8):281-3. Comment. [pmid: 7949433].
1668 Gregory WT, Lou JS, Stuyvesant A, et al. Quantitative electromyography of the anal sphincter after uncomplicated vaginal delivery. Obstet Gynecol. Aug. 2004;104(2):327-35. Case-Series. [pmid: 15292007].
1669 Grein U, Meyer WW. Local recurrent cancer after radical prostatectomy and incontinence. Is the artificial urinary sphincter a useful therapeutic option?. Urol Int. 2001;66(1):9-12. Case-series. [pmid: 11150943].
1670 Grey BR, Sheldon RR, Telford KJ, et al. Anterior anal sphincter repair can be of long term benefit: a 12-year case cohort from a single surgeon. BMC Surg. 2007;7:1. Case-series. [pmid: 17217528]. [pmcid: 1779765].
1671 Griebling TL, Kreder KJ Jr, Williams RD. Transurethral collagen injection for treatment of postprostatectomy urinary incontinence in men. Urology. Jun. 1997;49(6):907-12. Not eligible target population. [pmid: 9187699].
1672 Grieve T. Continence promotion among children with severe disabilities. Nurs Times. Oct 14–20. 1998;94(41):58-9. Comment. [pmid: 9832873].
1673 Griffith-Jones MD, MD PH. The Stamey endoscopic bladder neck suspension in the elderly. Br J Urol. Feb. 1990;65(2):170-2. Case-series. [pmid: 2317651].
1674 Griffith-Jones MD, Jarvis GJ, McNamara HM. Adverse urinary symptoms after total abdominal hysterectomy—fact or fiction?. Br J Urol. Mar. 1991;67(3):295-7. Case-series. [pmid: 2021819].
1675 Griffiths AN, Makam A, Edwards GJ. Should we actively screen for urinary and anal incontinence in the general gynaecology outpatients setting?—A prospective observational study. J Obstet Gynaecol. Jul. 2006;26(5):442-4. Not eligible outcomes. [pmid: 16846873].
1676 Griffiths D. Clinical studies of cerebral and urinary tract function in elderly people with urinary incontinence. Behav Brain Res. May. 1998;92(2):151-5. Not eligible outcomes. [pmid: 9638957].
1677 Griffiths D, Derbyshire S, Stenger A, et al. Brain control of normal and overactive bladder. J Urol. Nov. 2005;174(5):1862-7. Not eligible outcomes. [pmid: 16217325].
1678 Griffiths DJ, Harrison G, Moore K, et al. Variability of post-void residual urine volume in the elderly. Urol Res. 1996;24(1):23-6. Not eligible outcomes. [pmid: 8966837].
1679 Griffiths DJ, McCracken PN, Harrison GM, et al. Cerebral aetiology of urinary urge incontinence in elderly people. Age Ageing. May. 1994;23(3):246-50. Question 2. [pmid: 8085512].
1680 Griffiths DJ, McCracken PN, Harrison GM, et al. Urge incontinence and impaired detrusor contractility in the elderly. Neurourol Urodyn. 2002;21(2):126-31. Case-series. [pmid: 11857665].
1681 Griffiths DJ, McCracken PN, Harrison GM, et al. Urinary incontinence in the elderly: the brain factor. Scand J Urol Nephrol Suppl. 1994;157:83-8. Not eligible outcomes. [pmid: 7939456].
1682 Griffiths DJ, McCracken PN, Harrison GM, et al. Urge incontinence in elderly people: factors predicting the severity of urine loss before and after pharmacological treatment. Neurourol Urodyn. 1996;15(1):53-7. Case-series. [pmid: 8696356].
1683 Griffiths JM, Black NA, Pope C, et al. What determines the choice of procedure in stress incontinence surgery? The use of multilevel modeling. Int J Technol Assess Health Care. Summer. 1998;14(3):431-45. Not eligible outcomes. [pmid: 9780530].
1684 Grignaffini A, Bazzani F, Bertoli P, et al. Intravesicular prostaglandin E2 for the prophylaxis of urinary retention after colpohysterectomy. J Int Med Res. Mar–Apr. 1998;26(2):87-92. Not eligible exposure. [pmid: 9602987].
1685 Grills IS, Martinez AA, Hollander M, et al. High dose rate brachytherapy as prostate cancer monotherapy reduces toxicity compared to low dose rate palladium seeds. J Urol. Mar. 2004;171(3):1098-104. Not eligible level of evidence. [pmid: 14767279].
1686 Grimby A, Milsom I, Molander U, et al. The influence of urinary incontinence on the quality of life of elderly women. Age Ageing. Mar. 1993;22(2):82-9. Not eligible outcomes. [pmid: 8470564].
1687 Grimby A, Rosenhall U. Health-related quality of life and dizziness in old age. Gerontology. 1995;41(5):286-98. Not eligible level of evidence. [pmid: 8537013].
1688 Grimby A, Svanborg A. Morbidity and health-related quality of life among ambulant elderly citizens. Aging (Milano). Oct. 1997;9(5):356-64. Not eligible outcomes. [pmid: 9458996].
1689 Grinspun D. Bladder management for adults following head injury. Rehabil Nurs. Sep–Oct. 1993;18(5):300-5. Case- Reports. [pmid: 8066319].
1690 Grise P, Droupy S, Saussine C, et al. Transobturator tape sling for female stress incontinence with polypropylene tape and outside-in procedure: prospective study with 1 year of minimal follow-up and review of transobturator tape sling. Urology. Oct. 2006;68(4):759-63. Not eligible target population. [pmid: 17070348].
1691 Groen J, Amiel C, Bosch JL. Chronic pudendal nerve neuromodulation in women with idiopathic refractory detrusor overactivity incontinence: results of a pilot study with a novel minimally invasive implantable mini-stimulator. Neurourol Urodyn. 2005;24(3):226-30. Case-series. [pmid: 15825153].
1692 Groen J, Bosch JL. Bladder contraction strength parameters poorly predict the necessity of long-term catheterization after a pubovaginal rectus fascial sling procedure. J Urol. Sep. 2004;172(3):1006-9. Case-series. [pmid: 15311024].
1693 Gross JC. A comparison of the characteristics of incontinent and continent stroke patients in a rehabilitation program. Rehabil Nurs. May–Jun. 1998;23(3):132-40. Not eligible outcomes. [pmid: 9697584].
1694 Gross JC. Urinary incontinence and stroke outcomes. Arch Phys Med Rehabil. Jan. 2000;81(1):22-7. Not eligible outcomes. [pmid: 10638871].
1695 Grossklaus DJ, Franke JJ. Treatment of elderly women with urge incontinence in middle tennessee: a single institution practice-based study. Tenn Med. Dec. 2000;93(12):457-60. Case-series. [pmid: 11117074].
1696 Grotz RL, Pemberton JH, Ferrara A, et al. Ileal pouch pressures after defecation in continent and incontinent patients. Dis Colon Rectum. Nov. 1994;37(11):1073-7. Not eligible exposure. [pmid: 7956572].
1697 Groutz A, Blaivas JG, Chaikin DC, et al. Noninvasive outcome measures of urinary incontinence and lower urinary tract symptoms: a multicenter study of micturition diary and pad tests. J Urol. Sep. 2000;164(3 Pt 1):698-701. Not eligible outcomes. [pmid: 10953128].
1698 Groutz A, Blaivas JG, Chaikin DC, et al. The pathophysiology of post-radical prostatectomy incontinence: a clinical and video urodynamic study. J Urol. Jun. 2000;163(6):1767-70. Case-series. [pmid: 10799178].
1699 Groutz A, Blaivas JG, Hyman MJ, et al. Pubovaginal sling surgery for simple stress urinary incontinence: analysis by an outcome score. J Urol. May. 2001;165(5):1597-600. Case-series. [pmid: 11342925].
1700 Groutz A, Blaivas JG, Rosenthal JE. A simplified urinary incontinence score for the evaluation of treatment outcomes. Neurourol Urodyn. 2000;19(2):127-35. Not eligible outcomes. [pmid: 10679829].
1701 Groutz A, Chaikin DC, Theusen E, et al. Use of cadaveric solvent-dehydrated fascia lata for cystocele repair—preliminary results. Urology. Aug. 2001;58(2):179-83. Case-series. [pmid: 11489693].
1702 Groutz A, Gold R, Pauzner D, et al. Tension-free vaginal tape (TVT) for the treatment of occult stress urinary incontinence in women undergoing prolapse repair: a prospective study of 100 consecutive cases. Neurourol Urodyn. 2004;23(7):632-5. Case-series. [pmid: 15382184].
1703 Groutz A, Gordon D, Keidar R, et al. Stress urinary incontinence: prevalence among nulliparous compared with primiparous and grand multiparous premenopausal women. Neurourol Urodyn. 1999;18(5):419-25. Not eligible level of evidence. [pmid: 10494112].
1704 Groutz A, Gordon D, Wolman I, et al. The use of prophylactic Stamey bladder neck suspension to prevent post-operative stress urinary incontinence in clinically continent women undergoing genitourinary prolapse repair. Neurourol Urodyn. 2000;19(6):671-6. Not eligible target population. [pmid: 11071697].
1705 Grunberger W, Grunberger V, Wierrani F. Pelvic promontory fixation of the vaginal vault in sixty-two patients with prolapse after hysterectomy. J Am Coll Surg. Jan. 1994;178(1):69-72. Case-series. [pmid: 8156122].
1706 Guarino AH. Treatment of intractable constipation with orlistat: a report of three cases. Pain Med. Jul–Aug. 2005;6(4):327-8. Case- Reports. [pmid: 16083464].
1707 Guarisi T, Pinto-Neto AM, Herrmann V, et al. Urodynamics in climacteric women with urinary incontinence: correlation with route of delivery. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2002;13(6):366-71. discussion 71. Case-series. [pmid: 12466907].
1708 Guatelli S, Dall'Oglio B, Schiavon L, et al. Pubo-vaginal sling. Arch Ital Urol Androl. Mar. 2004;76(1):46-8. Case-series. [pmid: 15185825].
1709 Gudziak MR, McGuire EJ, Gormley EA. Urodynamic assessment of urethral sphincter function in post-prostatectomy incontinence. J Urol. Sep. 1996;156(3):1131-4. discussion 4–5. Not eligible outcomes. [pmid: 8709325].
1710 Guelinckx PJ, Sinsel NK, Gruwez JA. Anal sphincter reconstruction with the gluteus maximus muscle: anatomic and physiologic considerations concerning conventional and dynamic gluteoplasty. Plast Reconstr Surg. Aug. 1996;98(2):293-302. discussion 3–4. Case-series. [pmid: 8764718].
1711 Guerette N, Neimark M, Kopka SL, et al. Initial experience with a new method for the dynamic assessment of pelvic floor function in women: the Kolpexin Pull Test. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):39-43. discussion Not eligible level of evidence. [pmid: 14752597].
1712 Gufler H, DeGregorio G, Allmann KH, et al. Comparison of cystourethrography and dynamic MRI in bladder neck descent. J Comput Assist Tomogr. May–Jun. 2000;24(3):382-8. Not eligible outcomes. [pmid: 10864072].
1713 Gufler H, Laubenberger J, DeGregorio G, et al. Pelvic floor descent: dynamic MR imaging using a half-Fourier RARE sequence. J Magn Reson Imaging. Mar. 1999;9(3):378-83. Not eligible outcomes. [pmid: 10194706].
1714 Gufler H, Ohde A, Grau G, et al. Colpocystoproctography in the upright and supine positions correlated with dynamic MRI of the pelvic floor. Eur J Radiol. Jul. 2004;51(1):41-7. Case-series. [pmid: 15186883].
1715 Gui D, Cassetta E, Anastasio G, et al. Botulinum toxin for chronic anal fissure. Lancet. Oct 22. 1994;344(8930):1127-8. Case-series. [pmid: 7934496].
1716 Guihan M, Simmons B, Nelson A, et al. Spinal cord injury providers' perceptions of barriers to implementing selected clinical practice guideline recommendations. J Spinal Cord Med. Spring. 2003;26(1):48-58. Not eligible outcomes. [pmid: 12830970].
1717 Guillemot F, Bouche B, Gower-Rousseau C, et al. Biofeedback for the treatment of fecal incontinence. Long-term clinical results. Dis Colon Rectum. Apr. 1995;38(4):393-7. Not eligible target population. [pmid: 7720447].
1718 Guillemot F, Leroy J, Boniface M, et al. Functional assessment of coloanal anastomosis with reservoir and excision of the anal transition zone. Dis Colon Rectum. Nov. 1991;34(11):967-72. Case-series. [pmid: 1935475].
1719 Guillonneau B, Cathelineau X, Doublet JD, et al. Laparoscopic radical prostatectomy: the lessons learned. J Endourol. May. 2001;15(4):441-5. discussion 7–8. Case series. [pmid: 11394459].
1720 Gundian JC, Barrett DM, Parulkar BG. Mayo Clinic experience with the AS800 artificial urinary sphincter for urinary incontinence after transurethral resection of prostate or open prostatectomy. Urology. Apr. 1993;41(4):318-21. Case-series. [pmid: 8470315].
1721 Gungor T, Ekin M, Dogan M, et al. Influence of anterior colporrhaphy with colpoperineoplasty operations for stress incontinence and/or genital descent on sexual life. J Pak Med Assoc. Oct. 1997;47(10):248-50. Not eligible outcomes. [pmid: 9529850].
1722 Gunnarsson M, Mattiasson A. Female stress, urge, and mixed urinary incontinence are associated with a chronic and progressive pelvic floor/vaginal neuromuscular disorder: An investigation of 317 healthy and incontinent women using vaginal surface electromyography. Neurourol Urodyn. 1999;18(6):613-21. Not eligible outcomes. [pmid: 10529709].
1723 Gunningberg L. Risk, prevalence and prevention of pressure ulcers in three Swedish healthcare settings. J Wound Care. Jul. 2004;13(7):286-90. Not eligible outcomes. [pmid: 15977770].
1724 Guo Y, Palmer JL, Shen L, et al. Bowel and bladder continence, wound healing, and functional outcomes in patients who underwent sacrectomy. J Neurosurg Spine. Aug. 2005;3(2):106-10. Case-series. [pmid: 16370299].
1725 Gupta G, Aronow WS. Hormone replacement therapy. An analysis of efficacy based on evidence. Geriatrics 2002 Aug; 57(8):18–20, 3–4. Review
1726 Gupta PJ. Sphincterolysis: a novel approach towards chronic anal fissure. Eur Surg Res. 2006;38(2):122-6. Case-series. [pmid: 16699286].
1727 Gupta SK, Sathyan G. Pharmacokinetics of an oral once-a-day controlled-release oxybutynin formulation compared with immediate-release oxybutynin. J Clin Pharmacol. Mar. 1999;39(3):289-96. Not eligible outcomes. [pmid: 10073329].
1728 Gupta SK, Sathyan G, Lindemulder EA, et al. Quantitative characterization of therapeutic index: application of mixed-effects modeling to evaluate oxybutynin dose-efficacy and dose-side effect relationships. Clin Pharmacol Ther. Jun. 1999;65(6):672-84. Not eligible exposure. [pmid: 10391673].
1729 Gurel H, Gurel SA. Pelvic relaxation and associated risk factors: the results of logistic regression analysis. Acta Obstet Gynecol Scand. Apr. 1999;78(4):290-3. Not eligible outcomes. [pmid: 10203294].
1730 Gustafsson C, Ekstrom A, Brismar S, et al. Urinary incontinence after hysterectomy—three-year observational study. Urology. Oct. 2006;68(4):769-74. Not eligible level of evidence. [pmid: 17070350].
1731 Gustafsson UM, Graf W. Excision of anal fistula with closure of the internal opening: functional and manometric results. Dis Colon Rectum. Dec. 2002;45(12):1672-8. Case-series. [pmid: 12473893].
1732 Gutierrez-Molina M, Caminero Rodriguez A, Martinez Garcia C, et al. Small arterial granular degeneration in familial Binswanger's syndrome. Acta Neuropathol (Berl). 1994;87(1):98-105. Case Reports. [pmid: 8140899].
1733 Haab F, Cardozo L, Chapple C, et al. Long-term open-label solifenacin treatment associated with persistence with therapy in patients with overactive bladder syndrome. Eur Urol. Mar. 2005;47(3):376-84. Not eligible exposure. [pmid: 15716204].
1734 Haab F, Leach GE. Feasibility of outpatient percutaneous bladder neck suspension under local anesthesia. Urology. Oct. 1997;50(4):585-7. Not eligible target population. [pmid: 9338736].
1735 Haab F, Stewart L, Dwyer P. Darifenacin, an M3 selective receptor antagonist, is an effective and well-tolerated once-daily treatment for overactive bladder. Eur Urol. Apr. 2004;45(4):420-9. discussion 9. Not eligible exposure. [pmid: 15041104].
1736 Haab F, Trockman BA, Zimmern PE, et al. Quality of life and continence assessment of the artificial urinary sphincter in men with minimum 3.5 years of followup. J Urol. Aug. 1997;158(2):435-9. Case-series. [pmid: 9224318].
1737 Haab F, Zimmern PE, Leach GE. Urinary stress incontinence due to intrinsic sphincteric deficiency: experience with fat and collagen periurethral injections. J Urol. Apr. 1997;157(4):1283-6. Not eligible target population. [pmid: 9120921].
1738 Haadem K, Dahlstrom JA, Ling L. Maximum anal sphincter strength measured by the solid sphere test and anal pressure profiles. Eur J Surg. Sep. 1992;158(9):499-502. Not eligible outcomes. [pmid: 1358219].
1739 Haadem K, Dahlstrom JA, Lingman G. Anal sphincter function after delivery: a prospective study in women with sphincter rupture and controls. Eur J Obstet Gynecol Reprod Biol. Apr. 1990;35(1):7-13. Not eligible outcomes. [pmid: 2311820].
1740 Haadem K, Ling L, Ferno M, et al. Estrogen receptors in the external anal sphincter. Am J Obstet Gynecol. Feb. 1991;164(2):609-10. Not eligible outcomes. [pmid: 1992711].
1741 Haberl H, Tallen G, Michael T, et al. Surgical aspects and outcome of delayed tethered cord release. Zentralbl Neurochir. Nov. 2004;65(4):161-7. Not eligible target population. [pmid: 15551179].
1742 Hadley HR, Pineda EB. The urethral sling and stress urinary incontinence. West J Med. Sep. 1998;169(3):167-8. Comment. [pmid: 9771157]. [pmcid: 1305202].
1743 Hadzi-Djokic J, Stoiljkovic J, Basic D, et al. Clinical and urodynamic outcomes of tension-free vaginal tape procedure. Acta Chir Iugosl. 2004;51(3):57-60. Case-series.
1744 Haenggi W, Ammann M, Katz M, et al. Urethral isolation of Chlamydia trachomatis in women with urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Nov 3. 1991;42(1):53-6. Not eligible outcomes. [pmid: 1778292].
1745 Hafeez M, Asif S, Hanif H. Profile and repair success of vesico-vaginal fistula in Lahore. J Coll Physicians Surg Pak. Mar. 2005;15(3):142-4. Case-series. [pmid: 15808090].
1746 Haferkamp A, Freund T, Wagener N, et al. Distribution of neuropeptide Y-containing nerves in the neurogenic and non-neurogenic detrusor. BJU Int. Feb. 2006;97(2):393-9. Not eligible outcomes. [pmid: 16430653].
1747 Haferkamp A, Staehler G, Gerner HJ, et al. Dosage escalation of intravesical oxybutynin in the treatment of neurogenic bladder patients. Spinal Cord. Apr. 2000;38(4):250-4. Case-series. [pmid: 10822396].
1748 Hagan T. Nurses take the lead in continence work. Nurs Stand. Jun 27–Jul 3. 1990;4(40):24-8. Comment. [pmid: 2116851].
1749 Hagen S, Hanley J, Capewell A. Test-retest reliability, validity, and sensitivity to change of the urogenital distress inventory and the incontinence impact questionnaire. Neurourol Urodyn. 2002;21(6):534-9. Not eligible outcomes. [pmid: 12382243].
1750 Hagiwara N, Toyoda K, Uwatoko T, et al. Successful high dose glucocorticoid treatment for subacute neuromyelitis optica with systemic lupus erythematosus. Intern Med. Sep. 2005;44(9):998-1001. Case- Reports. [pmid: 16258221].
1751 Hahn I, Milsom I. Treatment of female stress urinary incontinence with a new anatomically shaped vaginal device (Conveen Continence Guard). Br J Urol. May. 1996;77(5):711-5. Not eligible target population. [pmid: 8689116].
1752 Hahnfeld LE, Nakada SY, Moon TD. Identification of microtacks in the bladder after laparoscopic pelvic surgery. Urology. Jul. 1999;54(1):162. Case Reports.
1753 Hahnloser D, Pemberton JH, Wolff BG, et al. Pregnancy and delivery before and after ileal pouch-anal anastomosis for inflammatory bowel disease: immediate and long-term consequences and outcomes. Dis Colon Rectum. Jul. 2004;47(7):1127-35. Not eligible target population. [pmid: 15164253].
1754 Haimanot RT. Neurological complications of endemic skeletal fluorosis, with special emphasis on radiculo-myelopathy. Paraplegia. May. 1990;28(4):244-51. Case-series. [pmid: 2172892].
1755 Hajebrahimi S, Corcos J, Lemieux MC. International consultation on incontinence questionnaire short form: comparison of physician versus patient completion and immediate and delayed self-administration. Urology. Jun. 2004;63(6):1076-8. Not eligible outcomes. [pmid: 15183953].
1756 Hakenberg OW, Ebermayer J, Manseck A, et al. Application of the Mitrofanoff principle for intermittent self-catheterization in quadriplegic patients. Urology. Jul. 2001;58(1):38-42. Case Reports. [pmid: 11445476].
1757 Halaska M, Ralph G, Wiedemann A, et al. Controlled, double-blind, multicentre clinical trial to investigate long-term tolerability and efficacy of trospium chloride in patients with detrusor instability. World J Urol. May. 2003;20(6):392-9. Not eligible exposure. [pmid: 12811500].
1758 Hale DS, Benson JT, Brubaker L, et al. Histologic analysis of needle biopsy of urethral sphincter from women with normal and stress incontinence with comparison of electromyographic findings. Am J Obstet Gynecol. Feb. 1999;180(2 Pt 1):342-8. Not eligible level of evidence. [pmid: 9988798].
1759 Hall AF, Theofrastous JP, Cundiff GW, et al. Interobserver and intraobserver reliability of the proposed International Continence Society, Society of Gynecologic Surgeons, and American Urogynecologic Society pelvic organ prolapse classification system. Am J Obstet Gynecol. Dec. 1996;175(6):1467-70. discussion 70–1. Not eligible outcomes. [pmid: 8987926].
1760 Hall J, Thomas DG. Surgical closure of the bulbar urethra for the treatment of intractable urinary incontinence in the paralysed patient. Br J Urol. Dec. 1998;82(6):912. Case-reports. [pmid: 9883236].
1761 Hall JD, Boyd JC, Lippert MC, et al. Why patients choose prostatectomy or brachytherapy for localized prostate cancer: results of a descriptive survey. Urology. Feb. 2003;61(2):402-7. Not eligible outcomes. [pmid: 12597956].
1762 Hall W, McCracken K, Osterweil P, et al. Frequency and predictors for postpartum fecal incontinence. Am J Obstet Gynecol. May. 2003;188(5):1205-7. Case-series. [pmid: 12748479].
1763 Hallbook O, Sjodahl R. Comparison between the colonic J pouch-anal anastomosis and healthy rectum: clinical and physiological function. Br J Surg. Oct. 1997;84(10):1437-41. Not eligible outcomes. [pmid: 9361608].
1764 Halligan S, Spence-Jones C, Kamm MA, et al. Dynamic cystoproctography and physiological testing in women with urinary stress incontinence and urogenital prolapse. Clin Radiol. Nov. 1996;51(11):785-90. Not eligible outcomes. [pmid: 8937321].
1765 Haltbakk J, Hanestad BR, Hunskaar S. Relevance and variability of the severity of incontinence, and increased daytime and night-time voiding frequency, associated with quality of life in men with lower urinary tract symptoms. BJU Int. Jul. 2005;96(1):83-7. Case series. [pmid: 15963126].
1766 Haltbakk J, Hanestad BR, Hunskaar S. How important are men's lower urinary tract symptoms (LUTS) and their impact on the quality of life (QOL)?. Qual Life Res. Sep. 2005;14(7):1733-41. Case series. [pmid: 16119184].
1767 Halverson AL, Hull TL. Long-term outcome of overlapping anal sphincter repair. Dis Colon Rectum. Mar. 2002;45(3):345-8. Comment. [pmid: 12068192].
1768 Halverson AL, Hull TL, Paraiso MF, et al. Outcome of sphincteroplasty combined with surgery for urinary incontinence and pelvic organ prolapse. Dis Colon Rectum. Oct. 2001;44(10):1421-6. Case-series. [pmid: 11598469].
1769 Hamalainen KJ, Raivio P, Antila S, et al. Biofeedback therapy in rectal prolapse patients. Dis Colon Rectum. Mar. 1996;39(3):262-5. Not eligible target population. [pmid: 8603545].
1770 Hamalainen KP, Sainio AP. Cutting seton for anal fistulas: high risk of minor control defects. Dis Colon Rectum. Dec. 1997;40(12):1443-6. discussion 7. Case-series. [pmid: 9407983].
1771 Hamdy H, Abdul Wahab AM, Fakhroo A, et al. Posterior sagittal anorectoplasty in adults. Br J Surg. Apr. 1994;81(4):601-2. Comment. [pmid: 8205447].
1772 Hamid R, Arya M, Khastgir J, et al. The treatment of male stress urinary incontinence with polydimethylsiloxane in compliant bladders following spinal cord injury. Spinal Cord. May. 2003;41(5):286-9. Case-series. [pmid: 12714991].
1773 Hamid R, Khastgir J, Arya M, et al. Experience of tension-free vaginal tape for the treatment of stress incontinence in females with neuropathic bladders. Spinal Cord. Feb. 2003;41(2):118-21. Case-series. [pmid: 12595875].
1774 Hamilton AS, Stanford JL, Gilliland FD, et al. Health outcomes after external-beam radiation therapy for clinically localized prostate cancer: results from the Prostate Cancer Outcomes Study. J Clin Oncol. May 1. 2001;19(9):2517-26. Case Series. [pmid: 11331331].
1775 Hammer BJ. An interdisciplinary approach to urinary incontinence. Geriatr Nurs. Nov–Dec. 1998;19(6):338-41. Comment. [pmid: 9919120].
1776 Hammerer P, Huland H. Urodynamic evaluation of changes in urinary control after radical retropubic prostatectomy. J Urol. Jan. 1997;157(1):233-6. Case-series. [pmid: 8976260].
1777 Hampel C, Wienhold D, Benken N, et al. Prevalence and natural history of female incontinence. Eur Urol. 1997;32(Suppl 2):3-12. Review and meta-analysis. [pmid: 9248806].
1778 Hamzeh R, Oligbo N. Tension-free tape procedure for a woman with a transplanted kidney. Bjog. Apr. 2005;112(4):508. Case Reports. [pmid: 15777454].
1779 Han MO, Lee NY, Park HS. Abdominal obesity is associated with stress urinary incontinence in Korean women. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):35-9. Not eligible level of evidence. [pmid: 16021328].
1780 Han PY, Ezquerro R, Pan KM, et al. Comorbidities associated with diabetic foot complications among Asian Americans in southern California. J Am Podiatr Med Assoc. Jan–Feb. 2003;93(1):37-41. Not eligible level of evidence. [pmid: 12533555].
1781 Han SJ, Park HJ, Kim CB, et al. Long-term follow-up of gracilis muscle transposition in children. Yonsei Med J. Sep. 1995;36(4):372-7. Not eligible target population. [pmid: 7483681].
1782 Han TR, Kim JH, Kwon BS. Chronic gastrointestinal problems and bowel dysfunction in patients with spinal cord injury. Spinal Cord. Jul. 1998;36(7):485-90. Case-series. [pmid: 9670385].
1783 Hancock R, Bender P, Dayhoff N, et al. Factors associated with nursing interventions to reduce incontinence in hospitalized older adults. Urol Nurs. Sep. 1996;16(3):79-85. Not eligible target population. [pmid: 9295797].
1784 Handa VL, Harvey L, Cundiff GW, et al. Perioperative complications of surgery for genital prolapse: does concomitant anti-incontinence surgery increase complications?. Urology. Mar. 2005;65(3):483-7. Not eligible outcomes. [pmid: 15780360].
1785 Handa VL, Harvey L, Cundiff GW, et al. Sexual function among women with urinary incontinence and pelvic organ prolapse. Am J Obstet Gynecol. Sep. 2004;191(3):751-6. Case-series. [pmid: 15467535].
1786 Handa VL, Jensen JK, Germain MM, et al. Banked human fascia lata for the suburethral sling procedure: a preliminary report. Obstet Gynecol. Dec. 1996;88(6):1045-9. Case-series. [pmid: 8942851].
1787 Handa VL, Jensen JK, Ostergard DR. The effect of patient position on proximal urethral mobility. Obstet Gynecol. Aug. 1995;86(2):273-6. Not eligible outcomes. [pmid: 7617360].
1788 Hanif MS, Saeed K, Sheikh MA. Surgical management of genitourinary fistula. J Pak Med Assoc. Jul. 2005;55(7):280-4. Case-series. [pmid: 16108510].
1789 Hankey GJ, Jamrozik K, Broadhurst RJ, et al. Five-year survival after first-ever stroke and related prognostic factors in the Perth Community Stroke Study. Stroke. Sep. 2000;31(9):2080-6. Not eligible level of evidence. [pmid: 10978033].
1790 Hankins GD. Lower thoracic spinal cord injury—a severe complication of shoulder dystocia. Am J Perinatol. Jul. 1998;15(7):443-4. Case-reports. [pmid: 9759912].
1791 Hanlon M, Cofone E. Patient with frequent liquid stools resulting in a chemical dermatitis and a perianal ulcer. J Wound Ostomy Continence Nurs. May. 1996;23(3):174-7. Case Reports. [pmid: 8845908].
1792 Hannappel J, Krieger S. Subjective and clinical results after transurethral resection and suprapubic prostatectomy in benign prostatic hypertrophy. Eur Urol. 1991;20(4):272-6. Case-series. [pmid: 1726084].
1793 Hannestad YS, Lie RT, Rortveit G, et al. Familial risk of urinary incontinence in women: population based cross sectional study. Bmj. Oct 16. 2004;329(7471):889-91. Not eligible level of evidence. [pmid: 15485965]. [pmcid: 523112].
1794 Hannestad YS, Rortveit G, Hunskaar S. Help-seeking and associated factors in female urinary incontinence. The Norwegian EPINCONT Study. Epidemiology of Incontinence in the County of Nord-Trondelag. Scand J Prim Health Care. Jun. 2002;20(2):102-7. Not eligible outcomes. [pmid: 12184708].
1795 Hanzal E, Berger E, Koelbl H. Levator ani muscle morphology and recurrent genuine stress incontinence. Obstet Gynecol. Mar. 1993;81(3):426-9. Case-series. [pmid: 8437799].
1796 Hanzal E, Joura EM, Haeusler G, et al. Influence of catheterisation on the results of sonographic urethrocystography in patients with genuine stress incontinence. Arch Gynecol Obstet. 1994;255(4):189-93. Not eligible outcomes. [pmid: 7695365].
1797 Hara I, Kawabata G, Miyake H, et al. Comparison of quality of life following laparoscopic and open prostatectomy for prostate cancer. J Urol. Jun. 2003;169(6):2045-8. Not eligible outcomes. [pmid: 12771715].
1798 Hara N, Koike H, Bilim V, et al. Placement of a urethral catheter into the ureter: An unexpected complication after retropubic suspension. Int J Urol. Feb. 2005;12(2):217-9. Case Reports. [pmid: 15733121].
1799 Harano M, Eto M, Nakamura M, et al. A pilot study of the assessment of the quality of life, functional results, and complications in patients with an ileal neobladder for invasive bladder cancer. Int J Urol. Feb. 2007;14(2):112-7. Case-series. [pmid: 17302566].
1800 Harari D, Malone-Lee JG. Oxybutynin and incontinence during grand mal seizures. Br J Urol. Dec. 1991;68(6):658. Case- Reports. [pmid: 1773301].
1801 Harari D, Sarkarati M, Gurwitz JH, et al. Constipation-related symptoms and bowel program concerning individuals with spinal cord injury. Spinal Cord. Jun. 1997;35(6):394-401. Case-series. [pmid: 9194264].
1802 Hardiman PJ, Drutz HP. Sacrospinous vault suspension and abdominal colposacropexy: success rates and complications. Am J Obstet Gynecol. Sep. 1996;175(3 Pt 1):612-6. Not eligible outcomes. [pmid: 8828423].
1803 Harewood GC, Coulie B, Camilleri M, et al. Descending perineum syndrome: audit of clinical and laboratory features and outcome of pelvic floor retraining. Am J Gastroenterol. Jan. 1999;94(1):126-30. Case-series. [pmid: 9934742].
1804 Harewood LM. Laparoscopic needle colposuspension for genuine stress incontinence. J Endourol. Aug. 1993;7(4):319-22. Case-reports. [pmid: 8252027].
1805 Harmanli OH, Dandolu V, Chatwani AJ, et al. Total colpocleisis for severe pelvic organ prolapse. J Reprod Med. Sep. 2003;48(9):703-6. Case-series. [pmid: 14562635].
1806 Harms BA, Andersen AB, Starling JR. The W ileal reservoir: long-term assessment after proctocolectomy for ulcerative colitis and familial polyposis. Surgery. Oct. 1992;112(4):638-46. discussion 46–8. Case-series. [pmid: 1329244].
1807 Harrington KL, Haskvitz EM. Managing a patient's constipation with physical therapy. Phys Ther. Nov. 2006;86(11):1511-9. Case-reports. [pmid: 17079751].
1808 Harris CF, Cooper CS, Hutcheson JC, et al. Appendicovesicostomy: the mitrofanoff procedure-a 15-year perspective. J Urol. Jun. 2000;163(6):1922-6. Case-series. [pmid: 10799230].
1809 Harris RL, Cundiff GW, Coates KW, et al. Urinary incontinence and pelvic organ prolapse in nulliparous women. Obstet Gynecol. Dec. 1998;92(6):951-4. Not eligible level of evidence. [pmid: 9840556].
1810 Harris RL, Cundiff GW, Theofrastous JP, et al. The value of intraoperative cystoscopy in urogynecologic and reconstructive pelvic surgery. Am J Obstet Gynecol. Dec. 1997;177(6):1367-9. discussion 9–71. Not eligible target population. [pmid: 9423737].
1811 Harrison GL, Memel DS. Urinary incontinence in women: its prevalence and its management in a health promotion clinic. Br J Gen Pract. Apr. 1994;44(381):149-52. Not eligible level of evidence. [pmid: 8185987]. [pmcid: 1238837].
1812 Hart AL, Kamm MA, Palmer JG, et al. An extra-ordinary cause of megacolon. Lancet. Jul 12. 1997;350(9071):110. Case-reports. [pmid: 9228964].
1813 Hart KJ, Palmer MH, Fitzgerald S. Perceived causes of urinary incontinence and reporting: a study with working women. Clin Nurs Res. Feb. 1999;8(1):84-92. Not eligible outcomes. [pmid: 10358493].
1814 Hartanto VH, Lightner DJ, Nitti VW. Endoscopic evacuation of Durasphere. Urology. Jul. 2003;62(1):135-7. Case- Reports. [pmid: 12837442].
1815 Hartmaier SL, Sloane PD, Guess HA, et al. The MDS Cognition Scale: a valid instrument for identifying and staging nursing home residents with dementia using the minimum data set. J Am Geriatr Soc. Nov. 1994;42(11):1173-9. Not eligible outcomes. [pmid: 7963204].
1816 Hartman EE, Oort FJ, Aronson DC, et al. Critical factors affecting quality of life of adult patients with anorectal malformations or Hirschsprung's disease. Am J Gastroenterol. May. 2004;99(5):907-13. Not eligible outcomes. [pmid: 15128359].
1817 Harvey MA, Kristjansson B, Griffith D, et al. The Incontinence Impact Questionnaire and the Urogenital Distress Inventory: a revisit of their validity in women without a urodynamic diagnosis. Am J Obstet Gynecol. Jul. 2001;185(1):25-31. Not eligible outcomes. [pmid: 11483899].
1818 Hasegawa H, Radley S, Keighley MR. Long-term results of cutting seton fistulotomy. Acta Chir Iugosl. 2000;47(4 Suppl 1):19-21. Case-series. [pmid: 11432237].
1819 Hashim H, Abrams P. Is the bladder a reliable witness for predicting detrusor overactivity?. J Urol. Jan. 2006;175(1):191-4. discussion 4–5. Not eligible outcomes. [pmid: 16406907].
1820 Hashimoto BE, Botoman VA. New challenge for endorectal sonography: diagnosis of fecal incontinence. J Ultrasound Med. Jul. 1993;12(7):375-8. Not eligible outcomes. [pmid: 8355330].
1821 Hashimoto K, Ohnishi N, Esa A, et al. Clinical efficacy of oxybutynin on sensory urgency as compared with that on motor urgency. Urol Int. 1999;62(1):12-6. Case-series. [pmid: 10436424].
1822 Haslam J. The prevalence of stress urinary incontinence in women. Nurs Times. May 18. 2004;100(20):71-3. No associative hypothesis tested. [pmid: 15176284].
1823 Hassan I, Horgan AF, Nivatvongs S. V-Y island flaps for repair of large perianal defects. Am J Surg. Apr. 2001;181(4):363-5. Case-series. [pmid: 11438274].
1824 Hassink EA, Rieu PN, Severijnen RS, et al. Adults born with high anorectal atresia—how do they manage?. Dis Colon Rectum. Jun. 1996;39(6):695-9. Case-series. [pmid: 8646960].
1825 Hassink EA, Rieu PN, Severijnen RS, et al. Are adults content or continent after repair for high anal atresia? A long-term follow-up study in patients 18 years of age and older. Ann Surg. Aug. 1993;218(2):196-200. Case-series. [pmid: 8343000]. [pmcid: 1242930].
1826 Hassouna MM, Heaton JP. Prostate cancer: 8. Urinary incontinence and erectile dysfunction. Cmaj. Jan 12. 1999;160(1):78-86. Case Reports. [pmid: 9934350]. [pmcid: 1229954].
1827 Hatada Y. Two-step surgical approach to labial adhesions in a postmenopausal woman. Acta Obstet Gynecol Scand. Nov. 2003;82(11):1054-5. Case Reports. [pmid: 14616281].
1828 Hatch ML. Conceptualization and treatment of bowel obsessions: two case reports. Behav Res Ther. Mar. 1997;35(3):253-7. Case- Reports. [pmid: 9125106].
1829 Hatem M, Fraser W, Lepire E. Postpartum urinary and anal incontinence: a population-based study of quality of life of primiparous women in Quebec. J Obstet Gynaecol Can. Jul. 2005;27(7):682-8. Not eligible level of evidence. [pmid: 16100623].
1830 Haugen V. Perineal skin care for patients with frequent diarrhea or fecal incontinence. Gastroenterol Nurs. May–Jun. 1997;20(3):87-90. Case Reports. [pmid: 9238936].
1831 Haugen V, Loehner D. Surgical and nonsurgical options for a patient with a retracted stoma and peristomal skin crease. J Wound Ostomy Continence Nurs. Jul. 2001;28(4):219-22. Case Reports. [pmid: 11452259].
1832 Hautmann RE. The ileal neobladder. Acta Urol Belg. 1991;59(2):227-40. Case-series. [pmid: 2053541].
1833 Hautmann RE, de Petriconi R, Gottfried HW, et al. The ileal neobladder: complications and functional results in 363 patients after 11 years of followup. J Urol. Feb. 1999;161(2):422-7. discussion 7–8. Not eligible level of evidence. [pmid: 9915417].
1834 Hautmann RE, Miller K, Steiner U, et al. The ileal neobladder: 6 years of experience with more than 200 patients. J Urol. Jul. 1993;150(1):40-5. Case series. [pmid: 8510272].
1835 Hautmann RE, Sauter TW, Wenderoth UK. Radical retropubic prostatectomy: morbidity and urinary continence in 418 consecutive cases. Urology. Feb. 1994;43(2 Suppl):47-51. Not eligible level of evidence. [pmid: 8116133].
1836 Hawkyard S, Poon P, Morgan DR. Sertoli tumour presenting with stress incontinence in a patient with testicular feminization. BJU Int. Aug. 1999;84(3):382-3. Case Reports. [pmid: 10468749].
1837 Haylen BT, Cerqui AJ, Meagher AP. Five-layer repair of rectovaginal fistula using a vaginal approach. A case report. Aust N Z J Obstet Gynaecol. Feb. 1999;39(1):131-3. Case Reports. [pmid: 10099771].
1838 Haylen BT, Chetty N, Logan V, et al. Is sensory urgency part of the same spectrum of bladder dysfunction as detrusor overactivity?. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2007;18(2):123-8. Not eligible level of evidence. [pmid: 16823541].
1839 Hayn MA, Greco SJ, Capuano K, et al. Compliance with pelvic floor exercise program: maintaining bladder symptom relief. Urol Nurs. Apr. 2000;20(2):129-31. Not eligible outcomes. [pmid: 11998123].
1840 He S, Hussain N, Li S, et al. Clinical and prognostic analysis of ossified ligamentum flavum in a Chinese population. J Neurosurg Spine. Nov. 2005;3(5):348-54. Case-series. [pmid: 16302628].
1841 Healy JC, Halligan S, Bartram CI, et al. Dynamic magnetic resonance imaging evaluation of the structural and functional results of postanal repair for neuropathic fecal incontinence. Dis Colon Rectum. Dec. 2002;45(12):1629-34. Not eligible target population. [pmid: 12473886].
1842 Healy JC, Halligan S, Reznek RH, et al. Patterns of prolapse in women with symptoms of pelvic floor weakness: assessment with MR imaging. Radiology. Apr. 1997;203(1):77-81. Not eligible outcomes. [pmid: 9122419].
1843 Heath T, Watson R. The causes of urinary incontinence in men. Nurs Older People. Sep. 2002;14(6):15-9. No associative hypothesis tested. [pmid: 12271549].
1844 Hebbard GS, Jenney AW, Gibson PR, et al. Chronic hepatic encephalopathy following portacaval shunt: management by loop ileostomy. Aust N Z J Surg. Mar. 1993;63(3):231-4. Case Reports. [pmid: 8311803].
1845 Hedin K, Petersson C, Wideback K, et al. Asymptomatic bacteriuria in a population of elderly in municipal institutional care. Scand J Prim Health Care. Sep. 2002;20(3):166-8. Not eligible outcomes. [pmid: 12389754].
1846 Heemsbergen WD, Peeters ST, Koper PC, et al. Acute and late gastrointestinal toxicity after radiotherapy in prostate cancer patients: consequential late damage. Int J Radiat Oncol Biol Phys. Sep 1. 2006;66(1):3-10. Not eligible outcomes. [pmid: 16814954].
1847 Hefti M, Landolt H. Presacral mass consisting of a meningocele and a Tarlov cyst: successful surgical treatment based on pathogenic hypothesis. Acta Neurochir (Wien). Apr. 2006;148(4):479-83. Case Reports. [pmid: 16322904].
1848 Hegarty PK, Power PC, O'Brien MF, et al. Longevity of the Marshall-Marchetti-Krantz procedure. Ann Chir Gynaecol. 2001;90(4):286-9. Case-series. [pmid: 11820418].
1849 Hegland A. A fresh start. Federal guidelines bring new perspective on incontinence. Contemp Longterm Care 1992 Jun; 15(6):78, 80, 100. Comment
1850 Hegland A. Incontinence: targeting treatment approaches. Provider 1994 Jul; 20(7):26–30, 2, 4–6. Comment
1851 Heikkinen M, Rintala R, Luukkonen P. Long-term anal sphincter performance after surgery for Hirschsprung's disease. J Pediatr Surg. Oct. 1997;32(10):1443-6. Not eligible target population. [pmid: 9349764].
1852 Heinzlef O, Paternotte C, Mahieux F, et al. Mapping of a complicated familial spastic paraplegia to locus SPG4 on chromosome 2p. J Med Genet. Feb. 1998;35(2):89-93. Case Reports. [pmid: 9507385]. [pmcid: 1051209].
1853 Heit M. Infectious peritonitis complicating suprapubic catheter removal. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(1):47-9. Case Reports. [pmid: 9260096].
1854 Heit M. Intraurethral ultrasonography: correlation of urethral anatomy with functional urodynamic parameters in stress incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(4):204-11. Not eligible outcomes. [pmid: 11005471].
1855 Heit M, Blackwell L, Ouseph R. Comorbidities affect the impact of urinary incontinence as measured by disease-specific quality of life instruments. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):6-11. discussion Not eligible level of evidence. [pmid: 15292980].
1856 Heit M, Blackwell L, Thomas S, et al. Prevalence and severity of urinary incontinence in kidney transplant recipients. Obstet Gynecol. Feb. 2004;103(2):352-8. Case-series. [pmid: 14754708].
1857 Heit M, Vogt V, Brubaker L. An alternative statistical approach for predicting prolonged catheterization after Burch colposuspension during reconstructive pelvic surgery. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(4):203-8. Not eligible outcomes. [pmid: 9449297].
1858 Helayel PE, Ceccon MS, Knaesel JA, et al. Urinary incontinence after bilateral parasacral sciatic-nerve block: report of two cases. Reg Anesth Pain Med. Jul–Aug. 2006;31(4):368-71. Case Reports. [pmid: 16857558].
1859 Helgason AR, Adolfsson J, Dickman P, et al. Waning sexual function—the most important disease-specific distress for patients with prostate cancer. Br J Cancer. Jun. 1996;73(11):1417-21. Not eligible target population. [pmid: 8645589].
1860 Helstrom L, Nilsson B. Impact of vaginal surgery on sexuality and quality of life in women with urinary incontinence or genital descensus. Acta Obstet Gynecol Scand. Jan. 2005;84(1):79-84. Not eligible outcomes. [pmid: 15603572].
1861 Helt M, Benson JT, Russell B, et al. Levator ani muscle in women with genitourinary prolapse: indirect assessment by muscle histopathology. Neurourol Urodyn. 1996;15(1):17-29. Not eligible outcomes. [pmid: 8696353].
1862 Helweg-Larsen S. Clinical outcome in metastatic spinal cord compression. A prospective study of 153 patients. Acta Neurol Scand. Oct. 1996;94(4):269-75. Not eligible exposure. [pmid: 8937539].
1863 Hely MA, Morris JG, Reid WG, et al. Sydney Multicenter Study of Parkinson's disease: non-L-dopa-responsive problems dominate at 15 years. Mov Disord. Feb. 2005;20(2):190-9. Case-series. [pmid: 15551331].
1864 Hemal AK, Kumar R, Nabi G. Post-cesarean cervicovesical fistula: technique of laparoscopic repair. J Urol. Apr. 2001;165(4):1167-8. Case-reports. [pmid: 11257662].
1865 Henderson JS, Kashka MS. Development and testing of the Urinary Incontinence Scales. Urol Nurs. Jun. 1999;19(2):109-19. Not eligible outcomes. [pmid: 10633762].
1866 Hendren WH. Construction of a female urethra using the vaginal wall and a buttock flap: experience with 40 cases. J Pediatr Surg. Feb. 1998;33(2):180-7. Case-series. [pmid: 9498383].
1867 Hendry WF. Bladder replacement by ileocystoplasty after cystectomy for cancer: comparison of two techniques. Br J Urol. Jul. 1996;78(1):74-9. Case-series. [pmid: 8795404].
1868 Henry LG, Cattey RP. Rectal prolapse. Surg Laparosc Endosc. Oct. 1994;4(5):357-60. Case-series. [pmid: 8000634].
1869 Henry T. Continence. Survey shows hidden problem. Nurs Times. Feb 14–20. 1996;92(7):62-6. Comment. [pmid: 8700724].
1870 Hensle TW, Reiley EA, Chang DT. The Malone antegrade continence enema procedure in the management of patients with spina bifida. J Am Coll Surg. Jun. 1998;186(6):669-74. Case-series. [pmid: 9632156].
1871 Henwood AM. A case of fecal incontinence. Home Healthc Nurse. Aug. 1997;15(8):558-9. Case Reports. [pmid: 9281938].
1872 Herbert JH. Postnatal pelvic floor screening clinics: a pilot study. Br J Community Nurs 2000 Aug; 5(8):370, 2, 4–6. Case-series
1873 Herbertsson G, Iosif CS. Surgical results and urodynamic studies 10 years after retropubic colpourethrocystopexy. Acta Obstet Gynecol Scand. May. 1993;72(4):298-301. Case-series. [pmid: 8389518].
1874 Herbst F, Kamm MA, Morris GP, et al. Gastrointestinal transit and prolonged ambulatory colonic motility in health and faecal incontinence. Gut. Sep. 1997;41(3):381-9. Not eligible outcomes. [pmid: 9378396]. [pmcid: 1891481].
1875 Herbst F, Teleky B. Alteration of maximum anal resting pressure by digital rectal examination prior to manometry: analysis of agreement between repeat measurements. Int J Colorectal Dis. 1994;9(4):207-10. Not eligible outcomes. [pmid: 7876726].
1876 Herman RM, Richter P, Walega P, et al. Anorectal sphincter function and rectal barostat study in patients following transanal endoscopic microsurgery. Int J Colorectal Dis. Nov. 2001;16(6):370-6. Case-series. [pmid: 11760898].
1877 Herman RM, Thor PJ, Sobocki J, et al. Anorectal and urinary dysfunction after surgery for rectal cancer. Folia Med Cracov. 2004;45(34):63-71. Case-series.
1878 Hernandez-Magro PM, Villanueva Saenz E, Alvarez-Tostado Fernandez F, et al. Endoanal sonography in the assessment of perianal endometriosis with external anal sphincter involvement. J Clin Ultrasound. May. 2002;30(4):245-8. Case-reports. [pmid: 11981936].
1879 Herr HW. Quality of life of incontinent men after radical prostatectomy. J Urol. Mar. 1994;151(3):652-4. Case-series. [pmid: 8308974].
1880 Herrmann V, Arya LA, Myers DL, et al. Urethral resistance measurement: a new method for evaluation of stress urinary incontinence in women. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):208-11. Not eligible exposure. [pmid: 15168003].
1881 Herschorn S, Becker D, Miller E, et al. Impact of a health education intervention in overactive bladder patients. Can J Urol. Dec. 2004;11(6):2430-7. Not eligible exposure. [pmid: 15636668].
1882 Herschorn S, Radomski SB. Fascial slings and bladder neck tapering in the treatment of male neurogenic incontinence. J Urol. Apr. 1992;147(4):1073-5. Case-series. [pmid: 1552586].
1883 Herschorn S, Steele DJ, Radomski SB. Followup of intraurethral collagen for female stress urinary incontinence. J Urol. Oct. 1996;156(4):1305-9. Case-series. [pmid: 8808860].
1884 Herschorn S, Thijssen AJ, Radomski SB. Experience with the hemi-Kock ileocystoplasty with a continent abdominal stoma. J Urol. May. 1993;149(5):998-1001. Case-series. [pmid: 8483253].
1885 Herwig R, Bruns F, Strasser H, et al. Late urologic effects after adjuvant irradiation in stage I endometrial carcinoma. Urology. Feb. 2004;63(2):354-8. Case-series. [pmid: 14972490].
1886 Hettiarachchi M, Garcea G, deSouza NM, et al. Evaluation of dysfunction following reconstruction of an anorectal anomaly. Pediatr Surg Int. Sep. 2002;18(56):405-9. Not eligible target population. [pmid: 12415366].
1887 Hetzer FH, Hahnloser D, Clavien PA, et al. Video-assisted sacral nerve stimulation. Tech Coloproctol. Jul. 2006;10(2):121-3. discussion 3–4. Case-series. [pmid: 16773288].
1888 Hetzer FH, Hahnloser D, Clavien PA, et al. Quality of life and morbidity after permanent sacral nerve stimulation for fecal incontinence. Arch Surg. Jan. 2007;142(1):8-13. Case-series. [pmid: 17224495].
1889 Hewitt WR, Sokol TP, Fleshner PR. Should HIV status alter indications for hemorrhoidectomy?. Dis Colon Rectum. Jun. 1996;39(6):615-8. Not eligible exposure. [pmid: 8646944].
1890 Hextall A, Bidmead J, Cardozo L, et al. The impact of the menstrual cycle on urinary symptoms and the results of urodynamic investigation. Bjog. Nov. 2001;108(11):1193-6. Not eligible target population. [pmid: 11762662].
1891 Hextall A, Boos K, Cardozo L, et al. Videocystourethrography with a ring pessary in situ. A clinically useful preoperative investigation for continent women with urogenital prolapse?. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(4):205-9. Question 4. [pmid: 9795825].
1892 Heymen S, Wexner SD, Gulledge AD. MMPI assessment of patients with functional bowel disorders. Dis Colon Rectum. Jun. 1993;36(6):593-6. Not eligible outcomes. [pmid: 8500378].
1893 Heyt GJ, Oh MK, Alemzadeh N, et al. Impaired rectoanal inhibitory response in scleroderma (systemic sclerosis): an association with fecal incontinence. Dig Dis Sci. Jun. 2004;49(6):1040-5. Not eligible outcomes. [pmid: 15309898].
1894 Hicken BL, Putzke JD, Richards JS. Bladder management and quality of life after spinal cord injury. Am J Phys Med Rehabil. Dec. 2001;80(12):916-22. Not eligible outcomes. [pmid: 11821674].
1895 Hida J, Yoshifuji T, Tokoro T, et al. Comparison of long-term functional results of colonic J-pouch and straight anastomosis after low anterior resection for rectal cancer: a five-year follow-up. Dis Colon Rectum. Oct. 2004;47(10):1578-85. Case-series. [pmid: 15540284].
1896 Hida J, Yoshifuji T, Tokoro T, et al. Long-term functional outcome of low anterior resection with colonic J-pouch reconstruction for rectal cancer in the elderly. Dis Colon Rectum. Sep. 2004;47(9):1448-54. Case-series. [pmid: 15486740].
1897 Higley P. With nature's help. Nurs Times. Aug 12–18. 1998;94(32):79-80. Case- Reports. [pmid: 9752189].
1898 Hill DE, Chantigian PM, Kramer SA. Pregnancy after augmentation cystoplasty. Surg Gynecol Obstet. Jun. 1990;170(6):485-7. Case-reports. [pmid: 2343363].
1899 Hill E, Haydel M. Conversion disorder presenting as hemiplegia and hemianesthesia with loss of neurologic reflexes: a case report. South Med J. Apr. 2006;99(4):380-2. Case Reports. [pmid: 16634248].
1900 Hill J, Corson RJ, Brandon H, et al. History and examination in the assessment of patients with idiopathic fecal incontinence. Dis Colon Rectum. May. 1994;37(5):473-7. Not eligible outcomes. [pmid: 8181410].
1901 Hill J, Hosker G, Kiff ES. Pudendal nerve terminal motor latency measurements: what they do and do not tell us. Br J Surg. Oct. 2002;89(10):1268-9. Not eligible outcomes. [pmid: 12296894].
1902 Hill J, Mumtaz A, Kiff ES. Pudendal neuropathy in patients with idiopathic faecal incontinence progresses with time. Br J Surg. Oct. 1994;81(10):1494-5. Not eligible outcomes. [pmid: 7820483].
1903 Hill K, Fanning S, Fennerty MB, et al. Endoanal ultrasound compared to anorectal manometry for the evaluation of fecal incontinence: a study of the effect these tests have on clinical outcome. Dig Dis Sci. Feb. 2006;51(2):235-40. case-series. [pmid: 16534661].
1904 Hill S, Khullar V, Wyndaele JJ, et al. Dose response with darifenacin, a novel once-daily M3 selective receptor antagonist for the treatment of overactive bladder: results of a fixed dose study. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):239-47. Not eligible exposure. [pmid: 15999217].
1905 Hilton P. Urodynamic findings in patients with urogenital fistulae. Br J Urol. Apr. 1998;81(4):539-42. Case-series. [pmid: 9598624].
1906 Hiltunen KM, Matikainen M. Clinical results of abdominal rectopexy for rectal prolapse. Ann Chir Gynaecol. 1991;80(3):263-6. Case-series. [pmid: 1759794].
1907 Hiltunen KM, Matikainen M. Improvement of continence after abdominal rectopexy for rectal prolapse. Int J Colorectal Dis. Feb. 1992;7(1):8-10. Case-series. [pmid: 1588227].
1908 Himpens J, Cadiere GB, Bruyns J, et al. Laparoscopic rectopexy according to Wells. Surg Endosc. Feb. 1999;13(2):139-41. Case-series. [pmid: 9918615].
1909 Hinata N, Shirakawa T, Okada H, et al. Quantitative analysis of the levels of expression of muscarinic receptor subtype RNA in the detrusor muscle of patients with overactive bladder. Mol Diagn. 2004;8(1):17-22. Not eligible outcomes. [pmid: 15230638].
1910 Hines SH, Seng JS, Messer KL, et al. Adherence to a behavioral program to prevent incontinence. West J Nurs Res. Feb. 2007;29(1):36-56. discussion 7–64. Not eligible outcomes. [pmid: 17228060].
1911 Hinze J, Junkin J. The latest in treatments for incontinence in women. Nebr Nurse. Jun–Aug. 2006;39(2):22-6. quiz 7–8. No associative hypothesis tested. [pmid: 16789399].
1912 Hirai K, Ishiko O, Sumi T, et al. Indifference and resignation of Japanese women toward urinary incontinence. Int J Gynaecol Obstet. Oct. 2001;75(1):89-91. Not eligible level of evidence. [pmid: 11597629].
1913 Hirato J. Left frontal tumor in a 46-year-old man with urinary incontinence and gait disturbance. Neuropathology. Dec. 2002;22(4):362-4. Case Reports. [pmid: 12564781].
1914 Hirono N, Kitagaki H, Kazui H, et al. Impact of white matter changes on clinical manifestation of Alzheimer's disease: A quantitative study. Stroke. Sep. 2000;31(9):2182-8. Case-series. [pmid: 10978049].
1915 Hirsch A, Weirauch G, Steimer B, et al. Treatment of female urinary incontinence with EMG-controlled biofeedback home training. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(1):7-10. Case-series. [pmid: 10207760].
1916 Hirsh T, Lembo T. Diagnosis and management of fecal incontinence in elderly patients. Am Fam Physician 1996 Oct; 54(5):1559–64, 69–70. Review
1917 Hirst GR, Arumugam PJ, Watkins AJ, et al. Antegrade continence enema in the treatment of obstructed defaecation with or without faecal incontinence. Tech Coloproctol. Dec. 2005;9(3):217-21. Not eligible exposure. [pmid: 16328126].
1918 Ho AM, Roth P, Cowan WD. Gaseous distention of the urinary bag indicating bladder perforation during laparoscopic pelvic procedures. Int J Gynaecol Obstet. Dec. 1996;55(3):297-8. Case Reports. [pmid: 9003958].
1919 Ho NC, Hadley DW, Jain PK, et al. Case 47: dural ectasia associated with Marfan syndrome. Radiology. Jun. 2002;223(3):767-71. Case Reports. [pmid: 12034948].
1920 Ho P, Law WL, Chan SC, et al. Functional outcome following low anterior resection with total mesorectal excision in the elderly. Int J Colorectal Dis. May. 2003;18(3):230-3. Case-series. [pmid: 12673488].
1921 Ho YH. Postanal sphincter repair for anterior resection anal sphincter injuries: report of three cases. Dis Colon Rectum. Aug. 2001;44(8):1218-20. Case-reports. [pmid: 11535866].
1922 Ho YH, Chiang JM, Tan M, et al. Biofeedback therapy for excessive stool frequency and incontinence following anterior resection or total colectomy. Dis Colon Rectum. Nov. 1996;39(11):1289-92. Case-series. [pmid: 8918441].
1923 Ho YH, Goh HS. Computerised 3-dimensional vector volume analysis—the role of a new method for assessing anal sphincter competence. Ann Acad Med Singapore. Mar. 1992;21(2):263-6. Not eligible outcomes. [pmid: 1519899].
1924 Ho YH, Goh HS. Unilateral anal electrosensation. Modified technique to improve quantification of anal sensory loss. Dis Colon Rectum. Mar. 1995;38(3):239-44. Not eligible outcomes. [pmid: 7882784].
1925 Ho YH, Goh HS. The neurophysiological significance of perineal descent. Int J Colorectal Dis. 1995;10(2):107-11. Not eligible outcomes. [pmid: 7636369].
1926 Ho YH, Low D, Goh HS. Bowel function survey after segmental colorectal resections. Dis Colon Rectum. Mar. 1996;39(3):307-10. Not eligible level of evidence. [pmid: 8603553].
1927 Ho YH, Tan M. Biofeedback therapy for bowel dysfunction following low anterior resection. Ann Acad Med Singapore. May. 1997;26(3):299-302. Case-series. [pmid: 9285021].
1928 Ho YH, Tan M, Chui CH, et al. Randomized controlled trial of primary fistulotomy with drainage alone for perianal abscesses. Dis Colon Rectum. Dec. 1997;40(12):1435-8. Not eligible outcomes. [pmid: 9407981].
1929 Hodder J. Shy Drager syndrome. Axone. Jun. 1997;18(4):75-9. Comment. [pmid: 9295481].
1930 Hodges AM. The Mitrofanoff urinary diversion for complex vesicovaginal fistulae: experience from Uganda. BJU Int. Sep. 1999;84(4):436-9. Case Reports. [pmid: 10468757].
1931 Hoffman MS, Arango H. Transvestibular retropubic bladder neck suspension. A pilot study. J Reprod Med. Mar. 1995;40(3):181-4. Case-series. [pmid: 7776300].
1932 Hoffman MS, Harris MS, Bouis PJ. Sacrospinous colpopexy in the management of uterovaginal prolapse. J Reprod Med. May. 1996;41(5):299-303. Case-series. [pmid: 8725751].
1933 Hoffman MS, LaPolla JP, Roberts WS, et al. Use of local flaps for primary anal reconstruction following perianal resection for neoplasia. Gynecol Oncol. Mar. 1990;36(3):348-52. Case-series. [pmid: 2318444].
1934 Hoffman MS, Roberts WS, Finan MA, et al. A comparative study of radical vulvectomy and modified radical vulvectomy for the treatment of invasive squamous cell carcinoma of the vulva. Gynecol Oncol. May. 1992;45(2):192-7. Case-series. [pmid: 1592286].
1935 Hoffmann BA, Timmcke AE, Gathright JB Jr, et al. Fecal seepage and soiling: a problem of rectal sensation. Dis Colon Rectum. Jul. 1995;38(7):746-8. Not eligible outcomes. [pmid: 7607037].
1936 Hofmann T, Gaensheimer S, Buchner A, et al. An unrandomized prospective comparison of urinary continence, bowel symptoms and the need for further procedures in patients with and with no adjuvant radiation after radical prostatectomy. BJU Int. Sep. 2003;92(4):360-4. Case-series. [pmid: 12930419].
1937 Hoggarth A, Waring M, Alexander J, et al. A controlled, three-part trial to investigate the barrier function and skin hydration properties of six skin protectants. Ostomy Wound Manage. Dec. 2005;51(12):30-42. Not eligible exposure.
1938 Hogstel MO, Nelson M. Anticipation and early detection can reduce bowel elimination complications. Geriatr Nurs. Jan–Feb. 1992;13(1):28-33. Case report. [pmid: 1317810].
1939 Hohenfellner M, Pannek J, Botel U, et al. Sacral bladder denervation for treatment of detrusor hyperreflexia and autonomic dysreflexia. Urology. Jul. 2001;58(1):28-32. Case-series.
1940 Hol M, van Bolhuis C, Vierhout ME. Vaginal ultrasound studies of bladder neck mobility. Br J Obstet Gynaecol. Jan. 1995;102(1):47-53. Not eligible level of evidence. [pmid: 7833310].
1941 Hollabaugh RS Jr, Dmochowski RR, Kneib TG, et al. Preservation of putative continence nerves during radical retropubic prostatectomy leads to more rapid return of urinary continence. Urology. Jun. 1998;51(6):960-7. Case-series. [pmid: 9609634].
1942 Hollabaugh RS Jr, Steiner MS, Sellers KD, et al. Neuroanatomy of the pelvis: implications for colonic and rectal resection. Dis Colon Rectum. Oct. 2000;43(10):1390-7. Not eligible target population. [pmid: 11052516].
1943 Hollenbeck BK, Lipp ER, Hayward RA, et al. Concurrent assessment of obstructive/irritative urinary symptoms and incontinence after radical prostatectomy. Urology. Mar. 2002;59(3):389-93. Not eligible level of evidence. [pmid: 11880076].
1944 Hollins S, Attard MT, von Fraunhofer N, et al. Mortality in people with learning disability: risks, causes, and death certification findings in London. Dev Med Child Neurol. Jan. 1998;40(1):50-6. Not eligible outcomes. [pmid: 9459217].
1945 Holmberg A, Graf W, Osterberg A, et al. Anorectal manovolumetry in the diagnosis of fecal incontinence. Dis Colon Rectum. May. 1995;38(5):502-8. Not eligible level of evidence. [pmid: 7736881].
1946 Holmdahl G, Sillen U. Boys with posterior urethral valves: outcome concerning renal function, bladder function and paternity at ages 31 to 44 years. J Urol. Sep. 2005;174(3):1031-4. discussion 4. Not eligible exposure. [pmid: 16094041].
1947 Holmes P. Mind over bladder. Nurs Times. Jan 24–30. 1990;86(4):16-7. Case Reports. [pmid: 2300476].
1948 Holmes SA, Christmas TJ, Kirby RS, et al. Cystectomy and substitution enterocystoplasty: alternative primary treatment for T2/3 bladder cancer. Br J Urol. Mar. 1992;69(3):260-4. Comment. [pmid: 1314683].
1949 Holmgren C, Hellberg D, Lanner L, et al. Quality of life after tension-free vaginal tape surgery for female stress incontinence. Scand J Urol Nephrol. 2006;40(2):131-7. Case-series. [pmid: 16608811].
1950 Holmgren C, Nilsson S, Lanner L, et al. Long-term results with tension-free vaginal tape on mixed and stress urinary incontinence. Obstet Gynecol. Jul. 2005;106(1):38-43. Case-series. [pmid: 15994615].
1951 Holroyd-Leduc JM, JM SE. Management of urinary incontinence in women: clinical applications. Jama. Feb 25. 2004;291(8):996-9. Case-reports. [pmid: 14982916].
1952 Holschneider AM, Pfrommer W, Gerresheim B. Results in the treatment of anorectal malformations with special regard to the histology of the rectal pouch. Eur J Pediatr Surg. Oct. 1994;4(5):303-9. Not eligible target population. [pmid: 7857888].
1953 Holubar S, Hyman N. Continence alterations after ileal pouch-anal anastomosis do not diminish quality of life. Dis Colon Rectum. Nov. 2003;46(11):1489-91. Not eligible target population. [pmid: 14605567].
1954 Holzer B, Matzel K, Schiedeck T, et al. Do geographic and educational factors influence the quality of life in rectal cancer patients with a permanent colostomy?. Dis Colon Rectum. Dec. 2005;48(12):2209-16. Not eligible outcomes. [pmid: 16228820].
1955 Hom D, Desautel MG, Lumerman JH, et al. Pubovaginal sling using polypropylene mesh and Vesica bone anchors. Urology. May. 1998;51(5):708-13. Case-series. [pmid: 9610583].
1956 Hombersley S. Guiding continence care. Elder Care. Feb. 2000;11(10):33. Comment. [pmid: 11215976].
1957 Homma Y, Ando T, Yoshida M, et al. Voiding and incontinence frequencies: variability of diary data and required diary length. Neurourol Urodyn. 2002;21(3):204-9. Not eligible outcomes. [pmid: 11948713].
1958 Homma Y, Kawabe K. Health-related quality of life of Japanese patients with overactive bladder treated with extended-release tolterodine or immediate-release oxybutynin: a randomized, placebo-controlled trial. World J Urol. Oct. 2004;22(4):251-6. Not eligible exposure. [pmid: 15455256].
1959 Homma Y, Kawabe K, Hayashi K. Urologic morbidity and its influence on global satisfaction with treatment outcome after radical prostatectomy for prostate cancer. Int J Urol. Nov. 1998;5(6):556-61. Case-series. [pmid: 9855124].
1960 Homma Y, Kawabe K, Kageyama S, et al. Injection of glutaraldehyde cross-linked collagen for urinary incontinence: two-year efficacy by self-assessment. Int J Urol. Mar. 1996;3(2):124-7. Not eligible target population. [pmid: 8689506].
1961 Homma Y, Koyama N. Minimal clinically important change in urinary incontinence detected by a quality of life assessment tool in overactive bladder syndrome with urge incontinence. Neurourol Urodyn. 2006;25(3):228-35. Not eligible target population. [pmid: 16532466].
1962 Homma Y, Paick JS, Lee JG, et al. Clinical efficacy and tolerability of extended-release tolterodine and immediate-release oxybutynin in Japanese and Korean patients with an overactive bladder: a randomized, placebo-controlled trial. BJU Int. Nov. 2003;92(7):741-7. Not eligible exposure. [pmid: 14616458].
1963 Homma Y, Uemura S. Use of the short form of King's Health Questionnaire to measure quality of life in patients with an overactive bladder. BJU Int. May. 2004;93(7):1009-13. Not eligible outcomes. [pmid: 15142153].
1964 Homma Y, Yoshida M, Seki N, et al. Symptom assessment tool for overactive bladder syndrome—overactive bladder symptom score. Urology. Aug. 2006;68(2):318-23. Not eligible outcomes. [pmid: 16904444].
1965 Honein K, Boujaoude J, Chemaly M, et al. How can a migraine cause faecal incontinence?. Gut. Dec. 2005;54(12):1817-24. Case Reports. [pmid: 16284292]. [pmcid: 1774799].
1966 Hong B, Park S, Kim HS, et al. Factors predictive of urinary retention after a tension-free vaginal tape procedure for female stress urinary incontinence. J Urol. Sep. 2003;170(3):852-6. Not eligible target population. [pmid: 12913715].
1967 Honjo H, Naya Y, Ukimura O, et al. Acupuncture on clinical symptoms and urodynamic measurements in spinal-cord-injured patients with detrusor hyperreflexia. Urol Int. 2000;65(4):190-5. Not eligible target population. [pmid: 11112867].
1968 Hool GR, Hull TL, Fazio VW. Surgical treatment of recurrent complete rectal prolapse: a thirty-year experience. Dis Colon Rectum. Mar. 1997;40(3):270-2. Case-series. [pmid: 9118739].
1969 Hool GR, Lieber ML, Church JM. Postoperative anal canal length predicts outcome in patients having sphincter repair for fecal incontinence. Dis Colon Rectum. Mar. 1999;42(3):313-8. Not eligible outcomes. [pmid: 10223749].
1970 Hope T, Keene J, Gedling K, et al. Behaviour changes in dementia. 1: Point of entry data of a prospective study. Int J Geriatr Psychiatry. Nov. 1997;12(11):1062-73. Case-series. [pmid: 9427090].
1971 Horbach NS, Ostergard DR. Predicting intrinsic urethral sphincter dysfunction in women with stress urinary incontinence. Obstet Gynecol. Aug. 1994;84(2):188-92. Not eligible outcomes. [pmid: 8041528].
1972 Horimoto Y, Matsumoto M, Akatsu H, et al. Autonomic dysfunctions in dementia with Lewy bodies. J Neurol. May. 2003;250(5):530-3. Case-series. [pmid: 12736730].
1973 Horstmann M, Schaefer T, Aguilar Y, et al. Neurogenic bladder treatment by doubling the recommended antimuscarinic dosage. Neurourol Urodyn. 2006;25(5):441-5. Not eligible target population. [pmid: 16847942].
1974 Hossack T, Solomon MJ, Young JM. Ano-cutaneous flap repair for complex and recurrent supra-sphincteric anal fistula. Colorectal Dis. Mar. 2005;7(2):187-92. Case-series. [pmid: 15720361].
1975 Houser EE, Bartholomew TH, Cookson MS, et al. A prospective evaluation of leak point pressure, bladder compliance and clinical status in myelodysplasia patients with tethered spinal cords. J Urol. Jan. 1994;151(1):177-80. discussion 80–1. Not eligible target population. [pmid: 8254809].
1976 Houston S, Thornton C, Emmanuel J, et al. Human T cell lymphotropic virus type 1 in Zimbabwe. Trans R Soc Trop Med Hyg. Mar–Apr. 1994;88(2):170-2. Case-reports. [pmid: 8036662].
1977 Hovdenak N, Karlsdottir A, Sorbye H, et al. Profiles and time course of acute radiation toxicity symptoms during conformal radiotherapy for cancer of the prostate. Acta Oncol. 2003;42(7):741-8. Case-series. [pmid: 14690160].
1978 Howard D, Delancey JO, Tunn R, et al. Racial differences in the structure and function of the stress urinary continence mechanism. Obstet Gynecol. May. 2000;95(5):713-7. Case-series. [pmid: 10775735]. [pmcid: 1283097].
1979 Howden NS, Zyczynski HM, Moalli PA, et al. Comparison of autologous rectus fascia and cadaveric fascia in pubovaginal sling continence outcomes. Am J Obstet Gynecol. May. 2006;194(5):1444-9. Case-series. [pmid: 16579930].
1980 Hoyte L, Jakab M, Warfield SK, et al. Levator ani thickness variations in symptomatic and asymptomatic women using magnetic resonance-based 3-dimensional color mapping. Am J Obstet Gynecol. Sep. 2004;191(3):856-61. Not eligible outcomes. [pmid: 15467553].
1981 Hoyte L, Schierlitz L, Zou K, et al. Two- and 3-dimensional MRI comparison of levator ani structure, volume, and integrity in women with stress incontinence and prolapse. Am J Obstet Gynecol. Jul. 2001;185(1):11-9. Not eligible exposure. [pmid: 11483897].
1982 Hruby G, Choo R, Lehman M, et al. Female clear cell adenocarcinoma arising within a urethral diverticulum. Can J Urol. Dec. 2000;7(6):1160-3. Case Reports. [pmid: 11151098].
1983 Hsieh CH, Su TH, Chang ST. Prevalence of and attitude toward urinary incontinence in Taiwanese women. Int J Gynaecol Obstet. Feb. 2005;88(2):152-3. Not eligible level of evidence. [pmid: 15694096].
1984 Hsieh CL, Sheu CF, Hsueh IP, et al. Trunk control as an early predictor of comprehensive activities of daily living function in stroke patients. Stroke. Nov. 2002;33(11):2626-30. Not eligible outcomes. [pmid: 12411652].
1985 Hsieh GC, Klutke JJ, Kobak WH. Low valsalva leak-point pressure and success of retropubic urethropexy. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(1):46-50. Case-series. [pmid: 11294532].
1986 Hsu EI, Hong EK, Lepor H. Influence of body weight and prostate volume on intraoperative, perioperative, and postoperative outcomes after radical retropubic prostatectomy. Urology. Mar. 2003;61(3):601-6. Case series. [pmid: 12639655].
1987 Hsu JW, Wang YC, Lin CC, et al. No evidence for association of alpha 1a adrenoceptor gene polymorphism and clozapine-induced urinary incontinence. Neuropsychobiology. 2000;42(2):62-5. Not eligible exposure. [pmid: 10940760].
1988 Hsu TH, Rackley RR, Abdelmalak JB, et al. Novel technique for combined repair of postirradiation vesicovaginal fistula and augmentation ileocystoplasty. Urology. Apr. 2002;59(4):597-9. Case- Reports. [pmid: 11927325].
1989 Hsu WM, Chen CC. Clinical and manometric evaluation of postoperative fecal soiling in patients with Hirschsprung's disease. J Formos Med Assoc. Jun. 1999;98(6):410-4. Case-series. [pmid: 10443064].
1990 Hu TW. Impact of urinary incontinence on health-care costs. J Am Geriatr Soc. Mar. 1990;38(3):292-5. Not eligible outcomes. [pmid: 2313010].
1991 Hu TW, Wagner TH. Health-related consequences of overactive bladder: an economic perspective. BJU Int. Sep. 2005;96(Suppl 1):43-5. Not eligible outcomes.
1992 Hu TW, Wagner TH, Bentkover JD, et al. Estimated economic costs of overactive bladder in the United States. Urology. Jun. 2003;61(6):1123-8. Not eligible outcomes. [pmid: 12809878].
1993 Hu TW, Wagner TH, Bentkover JD, et al. Costs of urinary incontinence and overactive bladder in the United States: a comparative study. Urology. Mar. 2004;63(3):461-5. Not eligible outcomes. [pmid: 15028438].
1994 Huang AJ, Brown JS, Kanaya AM, et al. Quality-of-life impact and treatment of urinary incontinence in ethnically diverse older women. Arch Intern Med. Oct 9. 2006;166(18):2000-6. Not eligible level of evidence. [pmid: 17030834].
1995 Huang AJ, Thom DH, Kanaya AM, et al. Urinary incontinence and pelvic floor dysfunction in Asian-American women. American Journal of Obstetrics and Gynecology. Nov. 2006;195(5):1331-7. Not eligible level of evidence. [pmid: 16643821]. [pmcid: 1630451].
1996 Huang KH, Kung FT, Liang HM, et al. Management of polypropylene mesh erosion after intravaginal midurethral sling operation for female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):437-40. Case-reports. [pmid: 15654499].
1997 Huang KH, Kung FT, Liang HM, et al. Concomitant pelvic organ prolapse surgery with TVT procedure. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):60-5. Case-series. [pmid: 15965574].
1998 Huang KH, Kung FT, Liang HM, et al. Concomitant surgery with tension-free vaginal tape. Acta Obstet Gynecol Scand. Oct. 2003;82(10):948-53. Not eligible outcomes. [pmid: 12956846].
1999 Huang WC, Yang JM. Sonographic appearance of a bladder calculus secondary to a suture from a bladder neck suspension. J Ultrasound Med. Nov. 2002;21(11):1303-5. Case Reports. [pmid: 12418771].
2000 Huang WC, Yang JM. Anatomic comparison between laparoscopic and open Burch colposuspension for primary stress urinary incontinence. Urology. Apr. 2004;63(4):676-81. discussion 81. Case-series. [pmid: 15072877].
2001 Huang WC, Yang JM, Yang SH. Cystoscopy to investigate suprapubic catheter blockage: plugging of the side holes by bladder mucosa. Bjog. May. 2005;112(5):670-1. Case Reports. [pmid: 15842295].
2002 Huang WC, Yang SH, Yang JM. Anatomical and functional significance of urogenital hiatus in primary urodynamic stress incontinence. Ultrasound Obstet Gynecol. Jan. 2006;27(1):71-7. Not eligible outcomes. [pmid: 16323154].
2003 Huang YH, Lin AT, Chen KK, et al. High failure rate using allograft fascia lata in pubovaginal sling surgery for female stress urinary incontinence. Urology. Dec. 2001;58(6):943-6. Case-series. [pmid: 11744464].
2004 Huber FT, Stein H, Siewert JR. Functional results after treatment of rectal prolapse with rectopexy and sigmoid resection. World J Surg. Jan–Feb. 1995;19(1):138-43. discussion 43. Case-series. [pmid: 7740801].
2005 Hubner WA, Schlarp OM. Treatment of incontinence after prostatectomy using a new minimally invasive device: adjustable continence therapy. BJU Int. Sep. 2005;96(4):587-94. Case-series. [pmid: 16104915].
2006 Huckabay C, Twiss C, Berger A, et al. A urodynamics protocol to optimally assess men with post-prostatectomy incontinence. Neurourol Urodyn. 2005;24(7):622-6. Case-series. [pmid: 16208638].
2007 Huebner ES, Surawicz CM. Diagnosis of celiac disease in a patient with fecal incontinence. Nat Clin Pract Gastroenterol Hepatol. Mar. 2006;3(3):172-5. quiz 6. Case Reports. [pmid: 16511552].
2008 Hueting WE, Gooszen HG, van Laarhoven CJ. Sexual function and continence after ileo pouch anal anastomosis: a comparison between a meta-analysis and a questionnaire survey. Int J Colorectal Dis. May. 2004;19(3):215-8. Not eligible target population. [pmid: 14564464].
2009 Hughes SF, Williams NS. Continent colonic conduit for the treatment of faecal incontinence associated with disordered evacuation. Br J Surg. Oct. 1995;82(10):1318-20. Case-series. [pmid: 7489152].
2010 Hugonnet CL, Danuser H, Springer JP, et al. Urethral sensitivity and the impact on urinary continence in patients with an ileal bladder substitute after cystectomy. J Urol. May. 2001;165(5):1502-5. Not eligible exposure. [pmid: 11342905].
2011 Hui-Chi H. A checklist for assessing the risk of falls among the elderly. J Nurs Res. Jun. 2004;12(2):131-42. Not eligible outcomes. [pmid: 15208777].
2012 Hull TL, Floruta C, Piedmonte M. Preliminary results of an outcome tool used for evaluation of surgical treatment for fecal incontinence. Dis Colon Rectum. Jun. 2001;44(6):799-805. Not eligible outcomes. [pmid: 11391139].
2013 Hullfish KL, Bovbjerg VE, Gibson J, et al. Patient-centered goals for pelvic floor dysfunction surgery: what is success, and is it achieved?. Am J Obstet Gynecol. Jul. 2002;187(1):88-92. Case-series. [pmid: 12114893].
2014 Hultman CS, Zenn MR, Agarwal T, et al. Restoration of fecal continence after functional gluteoplasty: long-term results, technical refinements, and donor-site morbidity. Ann Plast Surg. Jan. 2006;56(1):65-70. discussion -1. Case-series. [pmid: 16374099].
2015 Hung MJ, Ho ES, Shen PS, et al. Urgency is the core symptom of female overactive bladder syndrome, as demonstrated by a statistical analysis. J Urol. Aug. 2006;176(2):636-40. Not eligible target population. [pmid: 16813910].
2016 Hung MJ, Liu FS, Shen PS, et al. Analysis of two sling procedures using polypropylene mesh for treatment of stress urinary incontinence. Int J Gynaecol Obstet. Feb. 2004;84(2):133-41. Case-series. [pmid: 14871515].
2017 Hunskaar S. One hundred and fifty men with urinary incontinence. I. Demography and medical history. Scand J Prim Health Care. Mar. 1992;10(1):21-5. Not eligible target population. [pmid: 1589658].
2018 Hunskaar S, Sandvik H. One hundred and fifty men with urinary incontinence. III. Psychosocial consequences. Scand J Prim Health Care. Sep. 1993;11(3):193-6. Not eligible outcomes. [pmid: 8272651].
2019 Hunskaar S, Seim A, Freeman T. The journey of incontinent women from community to university clinic; implications for selection bias, gatekeeper function, and primary care. Fam Pract. Aug. 1996;13(4):363-8. Not eligible level of evidence. [pmid: 8872093].
2020 Hunt GM. Open spina bifida: outcome for a complete cohort treated unselectively and followed into adulthood. Dev Med Child Neurol. Feb. 1990;32(2):108-18. Not eligible target population. [pmid: 2186948].
2021 Hunter S, Anderson J, Hanson D, et al. Clinical trial of a prevention and treatment protocol for skin breakdown in two nursing homes. J Wound Ostomy Continence Nurs. Sep. 2003;30(5):250-8. Not eligible outcomes. [pmid: 14560283].
2022 Hurley DJ, Turner CL, Yalcin I, et al. Duloxetine for the treatment of stress urinary incontinence in women: an integrated analysis of safety. Eur J Obstet Gynecol Reprod Biol. Mar 1. 2006;125(1):120-8. Not eligible exposure. [pmid: 16188367].
2023 Hurst C. Self-care secrets. Talking about urinary incontinence. You're not alone. Loss of bladder control is more common than you think. Diabetes Forecast. Feb. 2003;56(2):94-5. Patient handouts.
2024 Hussain MS, Shuaib A, Siddiqi ZA. Spinal cord transient ischemic attacks: a possible role for abciximab. Neurology. Feb 22. 2005;64(4):761-2. Case- Reports. [pmid: 15728318].
2025 Hussain RM, Hartigan-Go K, Thomas SH, et al. Effect of oxybutynin on the QTc interval in elderly patients with urinary incontinence. Br J Clin Pharmacol. Jan. 1996;41(1):73-5. Not eligible outcomes. [pmid: 8824696].
2026 Hussar DA. New drugs: acamprosate calcium and solifenacin succinate. J Am Pharm Assoc (Wash DC). Jan–Feb. 2005;45(1):109-11. No associative hypothesis tested.
2027 Hutchings A, Black NA. Surgery for stress incontinence: a non-randomised trial of colposuspension, needle suspension and anterior colporrhaphy. Eur Urol. Apr. 2001;39(4):375-82. Not eligible outcomes. [pmid: 11306874].
2028 Hutchings A, Griffiths J, Black NA. Surgery for stress incontinence: factors associated with a successful outcome. Br J Urol. Nov. 1998;82(5):634-41. Not eligible target population. [pmid: 9839576].
2029 Hutchinson R, Mostafa AB, Grant EA, et al. Scintigraphic defecography: quantitative and dynamic assessment of anorectal function. Dis Colon Rectum. Dec. 1993;36(12):1132-8. Not eligible outcomes. [pmid: 8253010].
2030 Hvidman L, Hvidman L, Foldspang A, et al. Correlates of urinary incontinence in pregnancy. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):278-83. Not eligible level of evidence. [pmid: 12355285].
2031 Hwang YH, Person B, Choi JS, et al. Biofeedback therapy for rectal intussusception. Tech Coloproctol. Mar. 2006;10(1):11-5. discussion 5–6. Case-series. [pmid: 16528489].
2032 Hwang YM, Lee MC, Suh DC, et al. Coxiella (Q fever)-associated myelopathy. Neurology. Feb. 1993;43(2):338-42. Case Reports. [pmid: 8437699].
2033 Hyman MJ, Groutz A, Blaivas JG. Detrusor instability in men: correlation of lower urinary tract symptoms with urodynamic findings. J Urol. Aug. 2001;166(2):550-2. discussion 3. Not eligible outcomes. [pmid: 11458066].
2034 Hyman N. Endoanal advancement flap repair for complex anorectal fistulas. Am J Surg. Oct. 1999;178(4):337-40. Case-series. [pmid: 10587195].
2035 Hyman N. Incontinence after lateral internal sphincterotomy: a prospective study and quality of life assessment. Dis Colon Rectum. Jan. 2004;47(1):35-8. Case-series. [pmid: 14719148].
2036 Hyman NH, Fazio VW, Tuckson WB, et al. Consequences of ileal pouch-anal anastomosis for Crohn's colitis. Dis Colon Rectum. Aug. 1991;34(8):653-7. Case-series. [pmid: 1855421].
2037 Iglesias X, Espuna M. Surgical treatment of urinary stress incontinence using a method for postoperative adjustment of sling tension (Remeex System). Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):326-30. discussion 30. Case-series. [pmid: 14618309].
2038 Iglesias X, Espuna M, Puig M, et al. Pubic bone anchoring devices for the surgical treatment of urinary stress incontinence in patients with severe genital prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):314-8. Case-series. [pmid: 12355292].
2039 Iglicki F, Coffin B, Ille O, et al. Fecal incontinence after pelvic radiotherapy: evidences for a lumbosacral plexopathy. Report of a case. Dis Colon Rectum. Apr. 1996;39(4):465-7. Case- Reports. [pmid: 8878510].
2040 Ijland MM, Fischer DC, Kieback DG, et al. Midline intravaginal slingplasty for treatment of urinary stress incontinence: results of an independent audit up to 2 years after surgery. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):447-54. Case-series. [pmid: 15742119].
2041 Ikeda T, Tomita R, Koshinaga T. Anal mucosal electric sensation in postoperative patients with anorectal malformations. J Pediatr Surg. Jul. 2005;40(7):1146-50. Not eligible target population. [pmid: 16034760].
2042 Ikeuchi H, Kusunoki M, Shoji Y, et al. Clinico-physiological results after sphincter-saving resection for rectal carcinoma. Int J Colorectal Dis. 1996;11(4):172-6. Case-series. [pmid: 8876273].
2043 Ilbey O, Apaydin E, Gursan A, et al. Bladder leiomyoma: a rare cause of urinary stress incontinence. Arch Ital Urol Androl. Jun. 2000;72(2):85-7. Case Reports. [pmid: 10953395].
2044 Ilker Y, Tarcan T, Ozveren B, et al. Anterior urethropexy according to lapides: how effective is it in the treatment of genuine female stress incontinence?. Arch Esp Urol. Jan–Feb. 2003;56(1):95-9. Case-series. [pmid: 12701489].
2045 Indrekvam S, Fosse OA, Hunskaar S. A Norwegian national cohort of 3198 women treated with home-managed electrical stimulation for urinary incontinence—demography and medical history. Scand J Urol Nephrol. Feb. 2001;35(1):26-31. Not eligible outcomes. [pmid: 11291683].
2046 Infantino A, Masin A, Melega E, et al. Does surgery resolve outlet obstruction from rectocele?. Int J Colorectal Dis. 1995;10(2):97-100. Case-series. [pmid: 7636382].
2047 Infantino A, Melega E, Negrin P, et al. Striated anal sphincter electromyography in idiopathic fecal incontinence. Dis Colon Rectum. Jan. 1995;38(1):27-31. Not eligible outcomes. [pmid: 7813340].
2048 Inghilleri M, Conte A, Frasca V, et al. Venlafaxine and bladder function. Clin Neuropharmacol. Nov–Dec. 2005;28(6):270-3. Not eligible target population. [pmid: 16340381].
2049 Iosif CS. Effects of protracted administration of estriol on the lower genito urinary tract in postmenopausal women. Arch Gynecol Obstet. 1992;251(3):115-20. Case-series. [pmid: 1605675].
2050 Irer B, Aslan G, Cimen S, et al. Development of vesical calculi following tension-free vaginal tape procedure. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):245-6. Case- Reports. [pmid: 15875242].
2051 Irvine L. Paving the way to self-control. Maintaining continence in elderly people. Prof Nurse. Nov. 1991;7(2):94-7. Comment. [pmid: 1946499].
2052 Irwin DE, Milsom I, Kopp Z, et al. Impact of overactive bladder symptoms on employment, social interactions and emotional well-being in six European countries. BJU Int. Jan. 2006;97(1):96-100. Not eligible target population. [pmid: 16336336].
2053 Isbister WH. Anal incontinence surgery: a small personal experience. ANZ J Surg. May. 2001;71(5):290-1. Case-series. [pmid: 11374478].
2054 Isherwood PJ, Rane A. Comparative assessment of pelvic floor strength using a perineometer and digital examination. Bjog. Aug. 2000;107(8):1007-11. Not eligible outcomes. [pmid: 10955433].
2055 Ishigooka M, Hashimoto T, Hayami S, et al. Ice water test in patients with overactive bladder due to cerebrovascular accidents and bladder outlet obstruction. Urol Int. 1997;58(2):84-7. Not eligible outcomes. [pmid: 9096268].
2056 Ishigooka M, Hashimoto T, Hayami S, et al. Electrical pelvic floor stimulation: a possible alternative treatment for reflex urinary incontinence in patients with spinal cord injury. Spinal Cord. Jul. 1996;34(7):411-5. Not eligible target population. [pmid: 8963996].
2057 Ishigooka M, Hashimoto T, Izumiya K, et al. Membranous lipodystrophy (Nasu's disease): a rare cause of neuropathic urinary incontinence. Urol Int. 1993;50(3):179-81. Case Reports. [pmid: 8465487].
2058 Ishigooka M, Hashimoto T, Izumiya K, et al. Incidence of anal incontinence after long-term follow-up of patients treated by ureterosigmoidostomy. Int Urol Nephrol. 1993;25(5):455-60. Case-series. [pmid: 8270373].
2059 Ishigooka M, Hashimoto T, Sasagawa I, et al. Electrical pelvic floor stimulation by percutaneous implantable electrode. Br J Urol. Aug. 1994;74(2):191-4. Case-series. [pmid: 7921937].
2060 Ishigooka M, Ishii N, Hashimoto T, et al. Electrical stimulation of pelvic floor musculature by percutaneous implantable electrodes: a case report. Int Urol Nephrol. 1992;24(3):277-82. Case- Reports. [pmid: 1399385].
2061 Ishigooka M, Suzuki Y, Hashimoto T, et al. A new technique for sacral nerve stimulation: a percutaneous method for urinary incontinence caused by spinal cord injury. Br J Urol. Feb. 1998;81(2):315-8. Case-series. [pmid: 9488079].
2062 Ishiko O, Ushiroyama T, Saji F, et al. beta(2)-adrenergic agonists and pelvic floor exercises for female stress incontinence. Int J Gynaecol Obstet. Oct. 2000;71(1):39-44. Not eligible exposure. [pmid: 11044540].
2063 Ishunina TA, Kamphorst W, Swaab DF. Metabolic alterations in the hypothalamus and basal forebrain in vascular dementia. J Neuropathol Exp Neurol. Dec. 2004;63(12):1243-54. Not eligible outcomes. [pmid: 15624761].
2064 Iskander MN, Kapoor D. Pregnancy following tension-free vaginal taping. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2000;11(3):199-200. Case-reports. [pmid: 11484749].
2065 Ismael NN. A study on the menopause in Malaysia. Maturitas. Oct. 1994;19(3):205-9. Not eligible level of evidence. [pmid: 7799827].
2066 Ismael SS, Amarenco G, Bayle B, et al. Postpartum lumbosacral plexopathy limited to autonomic and perineal manifestations: clinical and electrophysiological study of 19 patients. J Neurol Neurosurg Psychiatry. Jun. 2000;68(6):771-3. Not eligible exposure. [pmid: 10811704]. [pmcid: 1736945].
2067 Ismael SS, Epstein T, Bayle B, et al. Bladder cooling reflex in patients with multiple sclerosis. J Urol. Oct. 2000;164(4):1280-4. Case-series. [pmid: 10992381].
2068 Isozaki E, Matsubara S, Hayashida T, et al. Morphometric study of nucleus ambiguus in multiple system atrophy presenting with vocal cord abductor paralysis. Clin Neuropathol. Sep–Oct. 2000;19(5):213-20. Case Reports. [pmid: 11048746].
2069 Ivey JF. Understanding and evaluating chronic urinary incontinence. J Fla Med Assoc. Dec. 1992;79(12):823-7. Secondary data analysis. [pmid: 1307239].
2070 Iwai N, Deguchi E, Kimura O, et al. Social quality of life for adult patients with anorectal malformations. J Pediatr Surg. Feb. 2007;42(2):313-7. Case-series. [pmid: 17270541].
2071 Jabs CF, Drutz HP. The role of intraoperative cystoscopy in prolapse and incontinence surgery. Am J Obstet Gynecol. Dec. 2001;185(6):1368-71. discussion 72–3. Not eligible exposure. [pmid: 11744911].
2072 Jackson J, Emerson L, Johnston B, et al. Biofeedback: a noninvasive treatment for incontinence after radical prostatectomy. Urol Nurs. Jun. 1996;16(2):50-4. Not eligible target population. [pmid: 8826153].
2073 Jackson LA, Benson P, Neuzil KM, et al. Burden of community-onset Escherichia coli bacteremia in seniors. J Infect Dis. May 1. 2005;191(9):1523-9. Not eligible outcomes. [pmid: 15809912].
2074 Jacobs PP, Scheuer M, Kuijpers JH, et al. Obstetric fecal incontinence. Role of pelvic floor denervation and results of delayed sphincter repair. Dis Colon Rectum. Jun. 1990;33(6):494-7. Case-series. [pmid: 2351003].
2075 Jacome EG, Tutera G, Mattox FT. Laparoscopic Burch urethropexy in a private clinical practice. J Am Assoc Gynecol Laparosc. Feb. 1999;6(1):39-44. Case-series. [pmid: 9971849].
2076 Jacquetin B, Wyndaele J. Tolterodine reduces the number of urge incontinence episodes in patients with an overactive bladder. Eur J Obstet Gynecol Reprod Biol. Sep. 2001;98(1):97-102. Not eligible exposure. [pmid: 11516807].
2077 Jaffin BW, Chang P, Spiera H. Fecal incontinence in scleroderma. Clinical features, anorectal manometric findings, and their therapeutic implications. J Clin Gastroenterol. Oct. 1997;25(3):513-7. Case-series. [pmid: 9412967].
2078 Jakobsen H, Kromann-Andersen B, Nielsen KK, et al. Pad weighing tests with 50% or 75% bladder filling. Does it matter?. Acta Obstet Gynecol Scand. Jul. 1993;72(5):377-81. Not eligible level of evidence. [pmid: 8392270].
2079 Jameson JS, Rogers J, Chia YW, et al. Pelvic floor function in multiple sclerosis. Gut. Mar. 1994;35(3):388-90. Not eligible outcomes. [pmid: 8150353]. [pmcid: 1374596].
2080 Jameson JS, Speakman CT, Darzi A, et al. Audit of postanal repair in the treatment of fecal incontinence. Dis Colon Rectum. Apr. 1994;37(4):369-72. Case-series. [pmid: 8168416].
2081 Janknegt RA, Hassouna MM, Siegel SW, et al. Long-term effectiveness of sacral nerve stimulation for refractory urge incontinence. Eur Urol. Jan. 2001;39(1):101-6. Not eligible target population. [pmid: 11173947].
2082 Janknegt RA, Heesakkers JP, Weil EH, et al. Electrically stimulated gracilis sphincter (dynamic graciloplasty) for treatment of intrinsic sphincter deficiency: a pilot study on feasibility and side effects. J Urol. Nov. 1995;154(5):1830-3. Not eligible target population. [pmid: 7563357].
2083 Janschek EC, Hohlagschwandtner M, Nather A, et al. A study of non-closure of the peritoneum at vaginal hysterectomy. Arch Gynecol Obstet. Feb. 2003;267(4):213-6. Not eligible outcomes. [pmid: 12592421].
2084 Janssen LW, van Dijke CF. Selection criteria for anterior rectal wall repair in symptomatic rectocele and anterior rectal wall prolapse. Dis Colon Rectum. Nov. 1994;37(11):1100-7. Case-series. [pmid: 7956577].
2085 Janssens F, Vandevenne J, Palmers Y. Chronic subdural hematoma of the lumbar spine. Jbr-Btr. Jan–Feb. 2004;87(1):51. Case Reports. [pmid: 15055337].
2086 Jarmy-Di Bella ZI, Girao MJ, Sartori MF, et al. Power Doppler of the urethra in continent or incontinent, pre- and postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2000;11(3):148-54. discussion 54–5. Not eligible outcomes. [pmid: 11484742].
2087 Jarrett ME, Matzel KE, Christiansen J, et al. Sacral nerve stimulation for faecal incontinence in patients with previous partial spinal injury including disc prolapse. Br J Surg. Jun. 2005;92(6):734-9. Not eligible target population. [pmid: 15838899].
2088 Jarrett ME, Matzel KE, Stosser M, et al. Sacral nerve stimulation for fecal incontinence following surgery for rectal prolapse repair: a multicenter study. Dis Colon Rectum. Jun. 2005;48(6):1243-8. Not eligible target population. [pmid: 15793647].
2089 Jarrett ME, Matzel KE, Stosser M, et al. Sacral nerve stimulation for faecal incontinence following a rectosigmoid resection for colorectal cancer. Int J Colorectal Dis. Sep. 2005;20(5):446-51. Case-series. [pmid: 15843939].
2090 Jarrett ME, Nicholls RJ, Kamm MA. Effect of sacral neuromodulation for faecal incontinence on sexual activity. Colorectal Dis. Sep. 2005;7(5):523-5. Case-series. [pmid: 16108893].
2091 Jarrett ME, Varma JS, Duthie GS, et al. Sacral nerve stimulation for faecal incontinence in the UK. Br J Surg. Jun. 2004;91(6):755-61. Case-series. [pmid: 15164447].
2092 Jawad SH, Ward AB, Jones P. Study of the relationship between premorbid urinary incontinence and stroke functional outcome. Clin Rehabil. Oct. 1999;13(5):447-52. Not eligible outcomes. [pmid: 10498352].
2093 Jehle EC, Haehnel T, Starlinger MJ, et al. Level of the anastomosis does not influence functional outcome after anterior rectal resection for rectal cancer. Am J Surg. Jan. 1995;169(1):147-52. discussion 52–3. Case-series. [pmid: 7817985].
2094 Jenkins KR, Fultz NH. Functional impairment as a risk factor for urinary incontinence among older Americans. Neurourol Urodyn. 2005;24(1):51-5. Not eligible level of evidence. [pmid: 15578629].
2095 Jenkins VR 2nd. Uterosacral ligament fixation for vaginal vault suspension in uterine and vaginal vault prolapse. Am J Obstet Gynecol. Dec. 1997;177(6):1337-43. discussion 43–4. Case-series. [pmid: 9423733].
2096 Jensen H, Nielsen K, Frimodt-Moller C. Abacterial cystitis in urinary incontinent females. Urol Int. 1990;45(1):20-4. Not eligible exposure. [pmid: 2305490].
2097 Jensen LL, Lowry AC. Biofeedback improves functional outcome after sphincteroplasty. Dis Colon Rectum. Feb. 1997;40(2):197-200. Case-series. [pmid: 9075757].
2098 Jensen LM, Aabech J, Lundvall F, et al. Female urethral diverticulum. Clinical aspects and a presentation of 15 cases. Acta Obstet Gynecol Scand. Sep. 1996;75(8):748-52. Case-series. [pmid: 8906011].
2099 Jervis LL. The pollution of incontinence and the dirty work of caregiving in a U.S. nursing home. Med Anthropol Q. Mar. 2001;15(1):84-99. Not eligible outcomes. [pmid: 11288620].
2100 Jess P, Christiansen J, Bech P. Quality of life after anterior resection versus abdominoperineal extirpation for rectal cancer. Scand J Gastroenterol. Oct. 2002;37(10):1201-4. Case-series. [pmid: 12408526].
2101 Jesudason SR, Mathai V, Gladwin G, et al. Functional outcome of overlapping sphincter repair for anal incontinence. Trop Gastroenterol. Oct–Dec. 1999;20(4):189-90. Comment. [pmid: 10769612].
2102 Jeter KF, Wagner DB. Incontinence in the American home. A survey of 36,500 people. J Am Geriatr Soc. Mar. 1990;38(3):379-83. Not eligible level of evidence. [pmid: 2313016].
2103 Jetzek-Zader M, Peterschulte G, Ludwig U, et al. Muscle weakness and paresthesia associated with epidural analgesia in a patient with an intrathecal neurofibrolipoma as part of a tethered cord syndrome. Anesth Analg. Jul. 2004;99(1):255-8. Case Reports. [pmid: 15281540].
2104 Jha S, Arunkalaivanan AS, Davis J. Surgical management of stress urinary incontinence: a questionnaire based survey. Eur Urol. May. 2005;47(5):648-52. Not eligible target population. [pmid: 15826757].
2105 Jiang JK, Lin JK. Does anastomotic method affect functional outcome of low anterior resection for rectal carcinoma?. Zhonghua Yi Xue Za Zhi (Taipei). Nov. 1997;60(5):252-8. Case-series. [pmid: 9509680].
2106 Jirovec MM. The impact of daily exercise on the mobility, balance and urine control of cognitively impaired nursing home residents. Int J Nurs Stud. 1991;28(2):145-51. Case-series. [pmid: 1894462].
2107 Jirovec MM, Jenkins J, Isenberg M, et al. Urine control theory derived from Roy's conceptual framework. Nurs Sci Q. Jul. 1999;12(3):251-5. Review. [pmid: 11847672].
2108 Jirovec MM, Wells TJ. Urinary incontinence in nursing home residents with dementia: the mobility-cognition paradigm. Appl Nurs Res. Aug. 1990;3(3):112-7. Case-series. [pmid: 2400208].
2109 Johannsson HO, Graf W, Pahlman L. Bowel habits in hemorrhoid patients and normal subjects. Am J Gastroenterol. Feb. 2005;100(2):401-6. Not eligible level of evidence. [pmid: 15667500].
2110 Johansson C, Hellstrom L, Ekelund P, et al. Urinary incontinence: a minor risk factor for hip fractures in elderly women. Maturitas. Aug. 1996;25(1):21-8. Not eligible outcomes. [pmid: 8887305].
2111 Johansson C, Molander U, Milsom I, et al. Association between urinary incontinence and urinary tract infections, and fractures in postmenopausal women. Maturitas. Apr. 1996;23(3):265-71. Not eligible outcomes. [pmid: 8794419].
2112 Johansson C, Nilsson BY, Mellgren A, et al. Paradoxical sphincter reaction and associated colorectal disorders. Int J Colorectal Dis. Jun. 1992;7(2):89-94. Case-series. [pmid: 1613301].
2113 John H. Bulbourethral composite suspension:: a new operative technique for post-prostatectomy incontinence. J Urol. May. 2004;171(5):1866-70. discussion 9–70. Case-series. [pmid: 15076295].
2114 John H, Hauri D. Seminal vesicle-sparing radical prostatectomy: a novel concept to restore early urinary continence. Urology. Jun. 2000;55(6):820-4. Case-series. [pmid: 10840084].
2115 John H, Hauri D, Leuener M, et al. Evidence of trigonal denervation and reinnervation after radical retropubic prostatectomy. J Urol. Jan. 2001;165(1):111-3. Case-series. [pmid: 11125377].
2116 Johnson DE, Muncie HL, O'Reilly JL, et al. An external urine collection device for incontinent women. Evaluation of long-term use. J Am Geriatr Soc. Sep. 1990;38(9):1016-22. Case-series. [pmid: 2212436].
2117 Johnson DW, ElHajj M, EL OB-B, et al. Necrotizing fasciitis after tension-free vaginal tape (TVT) placement. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):291-3. Case-Reports. [pmid: 14530844].
2118 Johnson JC, Jayadevappa R, Baccash PD, et al. Nonspecific presentation of pneumonia in hospitalized older people: age effect or dementia?. J Am Geriatr Soc. Oct. 2000;48(10):1316-20. Not eligible outcomes. [pmid: 11037021].
2119 Johnson ST. From incontinence to confidence. Am J Nurs 2000 Feb; 100(2):69–74, 6. Case- Reports
2120 Johnson TM 2nd, Bernard SL, Kincade JE, et al. Urinary incontinence and risk of death among community-living elderly people: results from the National Survey on Self-Care and Aging. J Aging Health. Feb. 2000;12(1):25-46. Not eligible level of evidence. [pmid: 10848124].
2121 Johnson TM 2nd, Burgio KL, Redden DT, et al. Effects of behavioral and drug therapy on nocturia in older incontinent women. J Am Geriatr Soc. May. 2005;53(5):846-50. Not eligible exposure. [pmid: 15877562].
2122 Johnson TM 2nd, Kincade JE, Bernard SL, et al. Self-care practices used by older men and women to manage urinary incontinence: results from the national follow-up survey on self-care and aging. J Am Geriatr Soc. Aug. 2000;48(8):894-902. Not eligible outcomes. [pmid: 10968292].
2123 Johnson TM, Ouslander JG, Uman GC, et al. Urinary incontinence treatment preferences in long-term care. J Am Geriatr Soc. Jun. 2001;49(6):710-8. Not eligible outcomes. [pmid: 11454108].
2124 Johnson VY, Hubbard D, Vordermark JS. Urologic manifestations of postpolio syndrome. J Wound Ostomy Continence Nurs. Jul. 1996;23(4):218-23. Not eligible level of evidence. [pmid: 8900675].
2125 Johnsson KE, Sass M. Cauda equina syndrome in lumbar spinal stenosis: case report and incidence in Jutland, Denmark. J Spinal Disord Tech. Aug. 2004;17(4):334-5. Case-series. [pmid: 15280766].
2126 Johnston TE, Betz RR, Smith BT, et al. Implantable FES system for upright mobility and bladder and bowel function for individuals with spinal cord injury. Spinal Cord. Dec. 2005;43(12):713-23. Case-series. [pmid: 16010275].
2127 Jomaa M. Combined tension-free vaginal tape and prolapse repair under local anaesthesia in patients with symptoms of both urinary incontinence and prolapse. Gynecol Obstet Invest. 2001;51(3):184-6. Not eligible outcomes. [pmid: 11306906].
2128 Jonas U, Hofner K, Madersbacher H, et al. Efficacy and safety of two doses of tolterodine versus placebo in patients with detrusor overactivity and symptoms of frequency, urge incontinence, and urgency: urodynamic evaluation. The International Study Group. World J Urol. 1997;15(2):144-51. Not eligible exposure. [pmid: 9144906].
2129 Jones D, Perese EF. Promoting self-management of urinary incontinence in a geropsychiatric day treatment program. J Psychosoc Nurs Ment Health Serv. May. 2003;41(5):38-43. Case-reports.
2130 Jones F. The accuracy of predicting functional recovery in patients following a stroke, by physiotherapists and patients. Physiother Res Int. 1998;3(4):244-56. Not eligible outcomes. [pmid: 9859133].
2131 Jones HJ, Swift RI, Blake H. A prospective audit of the usefulness of evacuating proctography. Ann R Coll Surg Engl. Jan. 1998;80(1):40-5. Not eligible outcomes. [pmid: 9579126]. [pmcid: 2502771].
2132 Jones JA, Mitchell ME, Rink RC. Improved results using a modification of the Young-Dees-Leadbetter bladder neck repair. Br J Urol. May. 1993;71(5):555-61. Not eligible target population. [pmid: 8518862].
2133 Jones JS. Management of urethral straddle injury after radical prostatectomy. Urology. May. 2002;59(5):773. Case Reports. [pmid: 11992922].
2134 Jones JS, Vasavada SP, Abdelmalak JB, et al. Sling may hasten return of continence after radical prostatectomy. Urology. Jun. 2005;65(6):1163-7. Case-series. [pmid: 15922423].
2135 Jones LC. Urinary incontinence: a major health issue for women. AWHONN Voice. Sep. 1995;3(8):9-10. Comment. [pmid: 7670419].
2136 Jones TV, Bunner SH. Approaches to urinary incontinence in a rural population: a comparison of physician assistants, nurse practitioners, and family physicians. J Am Board Fam Pract. May–Jun. 1998;11(3):207-15. Not eligible target population. [pmid: 9625512].
2137 Jongen VH, Brouwer WK. Comparison of the modified Pereyra procedure using permanent suture material and Burch urethropexy. Eur J Obstet Gynecol Reprod Biol. May. 1999;84(1):7-11. Case-series. [pmid: 10413219].
2138 Jonler M, Aagaard J, Fuglsig S, et al. The spontaneous course of urodynamically verified sphincter lesion after surgery for benign prostatic hyperplasia. Scand J Urol Nephrol. Mar. 1995;29(1):69-74. Case-series. [pmid: 7542401].
2139 Jonler M, Madsen FA, Rhodes PR, et al. A prospective study of quantification of urinary incontinence and quality of life in patients undergoing radical retropubic prostatectomy. Urology. Sep. 1996;48(3):433-40. Case-series. [pmid: 8804498].
2140 Jonler M, Messing EM, Rhodes PR, et al. Sequelae of radical prostatectomy. Br J Urol. Sep. 1994;74(3):352-8. Case-series. [pmid: 7953267].
2141 Jonler M, Nielsen OS, Wolf H. Urinary symptoms, potency, and quality of life in patients with localized prostate cancer followed up with deferred treatment. Urology. Dec. 1998;52(6):1055-62. discussion 63. Case-series. [pmid: 9836554].
2142 Jonler M, Ritter MA, Brinkmann R, et al. Sequelae of definitive radiation therapy for prostate cancer localized to the pelvis. Urology. Dec. 1994;44(6):876-82. No associative hypothesis tested. [pmid: 7985316].
2143 Joo JS, Latulippe JF, Alabaz O, et al. Long-term functional evaluation of straight coloanal anastomosis and colonic J-pouch: is the functional superiority of colonic J-pouch sustained?. Dis Colon Rectum. Jun. 1998;41(6):740-6. Case-series. [pmid: 9645742].
2144 Jorge JM, Ger GC, Gonzalez L, et al. Patient position during cinedefecography. Influence on perineal descent and other measurements. Dis Colon Rectum. Sep. 1994;37(9):927-31. Not eligible outcomes. [pmid: 8076493].
2145 Jorge JM, Habr-Gama A. The value of sphincter asymmetry index in anal incontinence. Int J Colorectal Dis. Nov. 2000;15(56):303-10. Not eligible level of evidence. [pmid: 11151434].
2146 Jorge JM, Wexner SD, Ehrenpreis ED, et al. Does perineal descent correlate with pudendal neuropathy?. Dis Colon Rectum. May. 1993;36(5):475-83. Not eligible outcomes. [pmid: 8387002].
2147 Jorge JM, Wexner SD, James K, et al. Recovery of anal sphincter function after the ileoanal reservoir procedure in patients over the age of fifty. Dis Colon Rectum. Oct. 1994;37(10):1002-5. Case-series. [pmid: 7924704].
2148 Jorge JM, Wexner SD, Marchetti F, et al. How reliable are currently available methods of measuring the anorectal angle?. Dis Colon Rectum. Apr. 1992;35(4):332-8. Not eligible outcomes. [pmid: 1582354].
2149 Jorgensen L, Lose G, Alexander N. Acute effect of norfenefrine on the urethral pressure profile in females with genuine stress incontinence. Urol Int. 1991;46(2):176-9. Not eligible outcomes. [pmid: 2053226].
2150 Jorion JL. Rectus fascial sling suspension of the vesicourethral anastomosis after radical prostatectomy. J Urol. Mar. 1997;157(3):926-8. Case-series. [pmid: 9072601].
2151 Jorion JL. Endoscopic treatment of bladder perforation after tension-free vaginal tape procedure. J Urol. Jul. 2002;168(1):197. Case Reports. [pmid: 12050528].
2152 Joseph AC, Chang MK. Comparison of behavior therapy methods for urinary incontinence following prostate surgery: a pilot study. Urol Nurs. Jun. 2000;20(3):203-4. [pmid: 11998139].
2153 Joseph AC, Sueppel C. Postprostatectomy urinary incontinence managed by behavioral methods. J Wound Ostomy Continence Nurs. May. 2000;27(3):194-8. Case- Reports. [pmid: 10814954].
2154 Joseph JV, Vicente I, Madeb R, et al. Robot-assisted vs pure laparoscopic radical prostatectomy: are there any differences?. BJU Int. Jul. 2005;96(1):39-42. Case-series. [pmid: 15963117].
2155 Jost WH. One hundred cases of anal fissure treated with botulin toxin: early and long-term results. Dis Colon Rectum. Sep. 1997;40(9):1029-32. Case-series. [pmid: 9293930].
2156 Jost WH. Electrostimulation in fecal incontinence: relevance of the sphincteric compound muscle action potential. Dis Colon Rectum. May. 1998;41(5):590-2. Case-series. [pmid: 9593240].
2157 Jost WH, Schimrigk K. Therapy of anal fissure using botulin toxin. Dis Colon Rectum. Dec. 1994;37(12):1321-4. Case-series. [pmid: 7995166].
2158 Jueng-Anuwat P, Roongruangsilp U, Kochakarn W, et al. Risk factors for stress urinary incontinence in middle aged and elderly Thai women. J Med Assoc Thai. Aug. 2001;84(8):1121-5. Not eligible level of evidence. [pmid: 11758846].
2159 Juhasz ES, Fozard B, Dozois RR, et al. Ileal pouch-anal anastomosis function following childbirth. An extended evaluation. Dis Colon Rectum. Feb. 1995;38(2):159-65. Case-series. [pmid: 7851170].
2160 Julia J, Yacoub M, Levy G. Labial fusion causing urinary incontinence in a postmenopausal female: a case report. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):360-1. Case-reports. [pmid: 14618318].
2161 Juma S, Little NA, Raz S. Basic evaluation of female urinary incontinence. Am J Kidney Dis. Oct. 1990;16(4):317-21. Guideline. [pmid: 2220777].
2162 Jundt K, Peschers UM, Dimpfl T. Long-term efficacy of pelvic floor re-education with EMG-controlled biofeedback. Eur J Obstet Gynecol Reprod Biol. Nov 15. 2002;105(2):181-5. Case-series. [pmid: 12381484].
2163 Junemann KP, Halaska M, Rittstein T, et al. Propiverine versus tolterodine: efficacy and tolerability in patients with overactive bladder. Eur Urol. Sep. 2005;48(3):478-82. Not eligible exposure. [pmid: 15967567].
2164 Jung BH, Bai SW, Chung BC. Urinary profile of endogenous steroids in postmenopausal women with stress urinary incontinence. J Reprod Med. Nov. 2001;46(11):969-74. Not eligible outcomes. [pmid: 11762153].
2165 Kaaki B, Gyves M, Goldman H. Spontaneous intrapartum vesicouterine fistula. Obstet Gynecol. Feb. 2006;107(2 Pt 2):449-50. Case-reports. [pmid: 16449144].
2166 Kabalin JN. Treatment of post-prostatectomy stress urinary incontinence with periurethral polytetrafluoroethylene paste injection. J Urol. Nov. 1994;152(5 Pt 1):1463-6. Not eligible target population. [pmid: 7523703].
2167 Kabalin JN. Addition of a second urethral cuff to enhance performance of the artificial urinary sphincter. J Urol. Oct. 1996;156(4):1302-4. Case-series. [pmid: 8808859].
2168 Kaefer M, Retik AB. The Mitrofanoff principle in continent urinary reconstruction. Urol Clin North Am. Nov. 1997;24(4):795-811. Review. [pmid: 9391532].
2169 Kafka NJ, Coller JA, Barrett RC, et al. Pudendal neuropathy is the only parameter differentiating leakage from solid stool incontinence. Dis Colon Rectum. Oct. 1997;40(10):1220-7. Not eligible outcomes. [pmid: 9336117].
2170 Kageyama S, Kawabe K, Suzuki K, et al. Collagen implantation for post-prostatectomy incontinence: early experience with a transrectal ultrasonographically guided method. J Urol. Nov. 1994;152(5 Pt 1):1473-5. Case-series. [pmid: 7933187].
2171 Kahn MA, Breitkopf CR, Valley MT, et al. Pelvic Organ Support Study (POSST) and bowel symptoms: straining at stool is associated with perineal and anterior vaginal descent in a general gynecologic population. Am J Obstet Gynecol. May. 2005;192(5):1516-22. Not eligible level of evidence. [pmid: 15902151].
2172 Kahn MA, Stanton SL. Posterior colporrhaphy: its effects on bowel and sexual function. Br J Obstet Gynaecol. Jan. 1997;104(1):82-6. Case-series. [pmid: 8988702].
2173 Kairaluoma M, Raivio P, Kupila J, et al. The role of biofeedback therapy in functional proctologic disorders. Scand J Surg. 2004;93(3):184-90. Case-series. [pmid: 15544072].
2174 Kairaluoma MV, Raivio P, Aarnio MT, et al. Immediate repair of obstetric anal sphincter rupture: medium-term outcome of the overlap technique. Dis Colon Rectum. Aug. 2004;47(8):1358-63. Case-series. [pmid: 15484350].
2175 Kaiwa Y, Kurokawa Y, Namiki K, et al. Outcome of laparoscopic rectopexy for complete rectal prolapse in patients older than 70 years versus younger patients. Surg Today. 2004;34(9):742-6. Case-series. [pmid: 15338345].
2176 Kajbafzadeh AM, Chubak N. Simultaneous Malone antegrade continent enema and Mitrofanoff principle using the divided appendix: report of a new technique for prevention of stoma complications. J Urol. Jun. 2001;165(6 Pt 2):2404-9. Case-series. [pmid: 11371987].
2177 Kakizaki H, Shibata T, Shinno Y, et al. Fascial sling for the management of urinary incontinence due to sphincter incompetence. J Urol. Mar. 1995;153(3 Pt 1):644-7. Not eligible target population. [pmid: 7861504].
2178 Kalra L, Dale P, Crome P. Evaluation of a clinical score for prognostic stratification of elderly stroke patients. Age Ageing. Nov. 1994;23(6):492-8. Not eligible level of evidence. [pmid: 9231944].
2179 Kalsi V, Popat RB, Apostolidis A, et al. Cost-consequence analysis evaluating the use of botulinum neurotoxin-A in patients with detrusor overactivity based on clinical outcomes observed at a single UK centre. Eur Urol. Mar. 2006;49(3):519-27. Not eligible target population. [pmid: 16413656].
2180 Kaltreider DL, Hu TW, Igou JF, et al. Can reminders curb incontinence?. Geriatr Nurs. Jan–Feb. 1990;11(1):17-9. Comment. [pmid: 2153615].
2181 Kammerer-Doak DN, Dominguez C, Harner K, et al. Surgical repair of fecal incontinence. Correlation of sonographic anal sphincter integrity with subjective cure. J Reprod Med. Jul. 1998;43(7):576-80. Case-series. [pmid: 9693407].
2182 Kane L, Chung T, Lawrie H, et al. The pubofascial anchor sling procedure for recurrent genuine urinary stress incontinence. BJU Int. Jun. 1999;83(9):1010-4. Case-series. [pmid: 10368246].
2183 Kane RL, Garrard J, Buchanan JL, et al. Improving primary care in nursing homes. J Am Geriatr Soc. Apr. 1991;39(4):359-67. Not eligible exposure. [pmid: 1672699].
2184 Kangas E, Hiltunen KM, Matikainen M. Anorectal function in Crohn's disease. Ann Chir Gynaecol. 1992;81(1):43-7. Not eligible level of evidence. [pmid: 1622051].
2185 Kannisto M, Rintala R. Bowel function in adults who have sustained spinal cord injury in childhood. Paraplegia. Dec. 1995;33(12):701-3. Not eligible exposure. [pmid: 8927408].
2186 Kao TC, Cruess DF, Garner D, et al. Multicenter patient self-reporting questionnaire on impotence, incontinence and stricture after radical prostatectomy. J Urol. Mar. 2000;163(3):858-64. Not eligible outcomes. [pmid: 10687992].
2187 Kaplan SA, Roehrborn CG, Dmochowski R, et al. Tolterodine extended release improves overactive bladder symptoms in men with overactive bladder and nocturia. Urology. Aug. 2006;68(2):328-32. Not eligible exposure. [pmid: 16904446].
2188 Kaplan SA, Santarosa RP, Te AE. Comparison of fascial and vaginal wall slings in the management of intrinsic sphincter deficiency. Urology. Jun. 1996;47(6):885-9. Case-series. [pmid: 8677582].
2189 Kapoor DS, Davila GW, Rosenthal RJ, et al. Pelvic floor dysfunction in morbidly obese women: pilot study. Obes Res. Jul. 2004;12(7):1104-7. Not eligible level of evidence. [pmid: 15292474].
2190 Kapoor R, Dubey D, Kumar A, et al. Modified bulbar urethral sling procedure for the treatment of male sphincteric incontinence. J Endourol. Jun. 2001;15(5):545-9. Case-series. [pmid: 11465337].
2191 Karadag A, Mentes BB, Ayaz S. Colostomy irrigation: results of 25 cases with particular reference to quality of life. J Clin Nurs. Apr. 2005;14(4):479-85. Case-series. [pmid: 15807755].
2192 Karakayali H, Bilgin N, Moray G, et al. Major urological complications in 1051 consecutive renal transplants. Transplant Proc. Aug. 1996;28(4):2339-40. Not eligible level of evidence. [pmid: 8769245].
2193 Karan A, Isikoglu M, Aksac B, et al. Hypermobility syndrome in 105 women with pure urinary stress incontinence and in 105 controls. Arch Gynecol Obstet. Jan. 2004;269(2):89-90. Not eligible outcomes. [pmid: 14648174].
2194 Karanjgaokar V, Amagada J, Ramaswamy S, et al. Successful use of TVT in the management of urodynamic stress incontinence in a treated case of carcinoma cervix. J Obstet Gynaecol. Apr. 2006;26(3):279-80. Case- Reports. [pmid: 16698650].
2195 Karanjia ND, Schache DJ, Heald RJ. Function of the distal rectum after low anterior resection for carcinoma. Br J Surg. Feb. 1992;79(2):114-6. Case-series. [pmid: 1555054].
2196 Karantanis E, Fynes M, Moore KH, et al. Comparison of the ICIQ-SF and 24-hour pad test with other measures for evaluating the severity of urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):111-6. discussion 6. Not eligible outcomes. [pmid: 15014938].
2197 Karantanis E, O'Sullivan R, Moore KH. The 24-hour pad test in continent women and men: normal values and cyclical alterations. Bjog. Jun. 2003;110(6):567-71. Not eligible outcomes. [pmid: 12798473].
2198 Kariv Y, Delaney CP, Casillas S, et al. Long-term outcome after laparoscopic and open surgery for rectal prolapse: a case-control study. Surg Endosc. Jan. 2006;20(1):35-42. Not eligible level of evidence. [pmid: 16374674].
2199 Karlbom U, Nilsson S, Pahlman L, et al. Defecographic study of rectal evacuation in constipated patients and control subjects. Radiology. Jan. 1999;210(1):103-8. Not eligible outcomes. [pmid: 9885594].
2200 Karlin GS, Badlani GH. Endourologic management of lower urinary tract dysfunction. Clin Geriatr Med. Feb. 1990;6(1):109-13. Review. [pmid: 2302649].
2201 Karon S. A team approach to bladder retraining: a pilot study. Urol Nurs. Aug. 2005;25(4):269-76. Case-series. [pmid: 16225344].
2202 Karoui S, Leroi AM, Koning E, et al. Results of sphincteroplasty in 86 patients with anal incontinence. Dis Colon Rectum. Jun. 2000;43(6):813-20. Case-series. [pmid: 10859083].
2203 Karoui S, Savoye-Collet C, Koning E, et al. Prevalence of anal sphincter defects revealed by sonography in 335 incontinent patients and 115 continent patients. AJR Am J Roentgenol. Aug. 1999;173(2):389-92. Not eligible outcomes. [pmid: 10430142].
2204 Karram MM, Partoll L, Bilotta V, et al. Factors affecting detrusor contraction strength during voiding in women. Obstet Gynecol. Nov. 1997;90(5):723-6. Not eligible outcomes. [pmid: 9351752].
2205 Karram MM, Partoll L, Rahe J. Efficacy of nonsurgical therapy for urinary incontinence. J Reprod Med. Apr. 1996;41(4):215-9. No associative hypothesis tested. [pmid: 8728070].
2206 Katlowitz NM, Karwa G, Lautin E. Stress incontinence secondary to a vesicourethral fistula: case report. Urol Radiol. 1990;12(1):37-8. Case- reports. [pmid: 2333673].
2207 Kato H. Incorrect positioning of an indwelling urethral catheter in the ureter. Int J Urol. Jul. 1997;4(4):417-8. Case Reports. [pmid: 9256334].
2208 Kato H, Igawa Y, Ogawa A. Incontinent ileal tube repaired by infolding with the ileal pouch wall. Int J Urol. Jul. 1997;4(4):428-30. Case Reports. [pmid: 9256338].
2209 Kattan SA. Maternal urological injuries associated with vaginal deliveries: change of pattern. Int Urol Nephrol. 1997;29(2):155-61. Case-series. [pmid: 9241541].
2210 Katti G. An evaluation of transanal endoscopic microsurgery for rectal adenoma and carcinoma. Jsls. Apr–Jun. 2004;8(2):123-6. Case-series. [pmid: 15119655].
2211 Kaum HJ, Wolff F. TVT: on midurethral tape positioning and its influence on continence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):110-5. discussion 5. Case-series. [pmid: 12054178].
2212 Kaur G, Gardiner A, Duthie GS. Rectoanal reflex parameters in incontinence and constipation. Dis Colon Rectum. Jul. 2002;45(7):928-33. Not eligible outcomes. [pmid: 12130882].
2213 Kaur G, Gardiner A, Duthie GS. A new method of assessing anal sphincter integrity using inverted vectormanometry. Dis Colon Rectum. Aug. 2006;49(8):1160-6. Not eligible outcomes. [pmid: 16708160].
2214 Kavallaris A, Kohler C, Diebolder H, et al. Repair of prolapse with vaginal sacrocolporectopexy: technique and results. Eur J Obstet Gynecol Reprod Biol. Oct 1. 2005;122(2):237-42. Case-series. [pmid: 15950362].
2215 Kawashima H, Hirai K, Okada N, et al. The importance of studying pressure-flow for predicting postoperative voiding difficulties in women with stress urinary incontinence: a preliminary study that correlates low Pdet × Qave with postoperative residual urine. Urol Res. May. 2004;32(2):84-8. Case-series. [pmid: 15067432].
2216 Kawsar M, Goh BT. Spinal schwannoma as a cause of erectile dysfunction with urinary incontinence and groin and testicular pain. Int J STD AIDS. Aug. 2002;13(8):584-5. Case-reports. [pmid: 12194747].
2217 Kayaba H, Kodama K, Shirayama K, et al. Evaluation of ability to defecate using saline evacuation from the rectum. Dis Colon Rectum. Oct. 1997;40(10 Suppl):S96-8. Not eligible exposure. [pmid: 9378020].
2218 Kayano CE, Sartori MG, Baracat EC, et al. Vaginal hysterectomy allied with Kelly-Kennedy surgery and perineal repair for the treatment of patients with a prolapsed uterus and urinary stress incontinence. Clin Exp Obstet Gynecol. 2002;29(1):27-30. Case- series. [pmid: 12013087].
2219 Kaye KW, Creed KE, Wilson GJ, et al. Urinary continence after radical retropubic prostatectomy. Analysis and synthesis of contributing factors: a unified concept. Br J Urol. Sep. 1997;80(3):444-501. Case series. [pmid: 9313665].
2220 Kayigil O. Our changing strategies on bladder neck suspension operations. Int Urol Nephrol. 1999;31(5):647-54. Case-series. [pmid: 10755355].
2221 Kayigil O, Biri A. Double forced sling by combining in situ vaginal wall and Infast pubic bone suburethral stabilization techniques: a new method. J Urol. Jun. 2002;167(6):2481-3. Case-series. [pmid: 11992062].
2222 Kayigil O, Iftekhar Ahmed S, Metin A. The coexistence of intrinsic sphincter deficiency with type II stress incontinence. J Urol. Oct. 1999;162(4):1365-6. Not eligible outcomes. [pmid: 10492198].
2223 Keachie J. Continence. Island life. Nurs Times 1993 Sep 29–Oct 5; 89(39):72, 4, 6. Comment
2224 Keane DP, Eckford SD, Shepherd AM, et al. Referral patterns and diagnoses in women attending a urodynamic unit. Bmj. Oct 3. 1992;305(6857):808. Secondary data analysis.
2225 Keane DP, Sims TJ, Abrams P, et al. Analysis of collagen status in premenopausal nulliparous women with genuine stress incontinence. Br J Obstet Gynaecol. Sep. 1997;104(9):994-8. Not eligible outcomes. [pmid: 9307523].
2226 Keane PF, Walsh IK, Kernohan RM. The artificial urinary sphincter. A new solution for incontinent patients. Ulster Med J. Oct. 1993;62(2):132-6. Case-series. [pmid: 8303795]. [pmcid: 2449053].
2227 Keil K. Urogenital atrophy: diagnosis, sequelae, and management. Curr Womens Health Rep. Aug. 2002;2(4):305-11. Comment. [pmid: 12150759].
2228 Kelleher C, Cardozo L, Kobashi K, et al. Solifenacin: as effective in mixed urinary incontinence as in urge urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):382-8. Secondary data pooled analysis. [pmid: 16283422].
2229 Keller PA, Sinkovic SP, Miles SJ. Skin dryness: a major factor in reducing incontinence dermatitis. Ostomy Wound Manage. Sep–Oct. 1990;30:60-4. Not eligible outcomes. [pmid: 2080978].
2230 Keller SL. Urinary incontinence: occurrence, knowledge, and attitudes among women aged 55 and older in a rural Midwestern setting. J Wound Ostomy Continence Nurs. Jan. 1999;26(1):30-8. Not eligible level of evidence. [pmid: 10036422].
2231 Kemp MG. Protecting the skin from moisture and associated irritants. J Gerontol Nurs. Sep. 1994;20(9):8-14. Not eligible outcomes. [pmid: 7930399].
2232 Kendirci M, Gupta S, Shaw K, et al. Synchronous prosthetic implantation through a transscrotal incision: an outcome analysis. J Urol. Jun. 2006;175(6):2218-22. Case-series. [pmid: 16697843].
2233 Kenefick NJ. Sacral nerve neuromodulation for the treatment of lower bowel motility disorders. Ann R Coll Surg Engl. Nov. 2006;88(7):617-23. No associative hypothesis tested. [pmid: 17132307]. [pmcid: 1963799].
2234 Kenefick NJ, Emmanuel A, Nicholls RJ, et al. Effect of sacral nerve stimulation on autonomic nerve function. Br J Surg. Oct. 2003;90(10):1256-60. Case-series. [pmid: 14515296].
2235 Kenefick NJ, Vaizey CJ, Cohen RC, et al. Medium-term results of permanent sacral nerve stimulation for faecal incontinence. Br J Surg. Jul. 2002;89(7):896-901. Case-series. [pmid: 12081740].
2236 Kenefick NJ, Vaizey CJ, Malouf AJ, et al. Injectable silicone biomaterial for faecal incontinence due to internal anal sphincter dysfunction. Gut. Aug. 2002;51(2):225-8. Case-series. [pmid: 12117884]. [pmcid: 1773312].
2237 Kenefick NJ, Vaizey CJ, Nicholls RJ, et al. Sacral nerve stimulation for faecal incontinence due to systemic sclerosis. Gut. Dec. 2002;51(6):881-3. Case-series. [pmid: 12427794]. [pmcid: 1773465].
2238 Kennedy A. Continence. Island education. Nurs Times. Nov 24–30. 1993;89(47):74-7. Comment. [pmid: 8265394].
2239 Kennedy CM, Nygaard IE, Saftlas A, et al. Vulvar disease: a pelvic floor pain disorder?. Am J Obstet Gynecol. Jun. 2005;192(6):1829-34. discussion 34–5. Not eligible outcomes. [pmid: 15970821].
2240 Kennedy ML, Lubowski DZ, King DW. Transanal endoscopic microsurgery excision: is anorectal function compromised?. Dis Colon Rectum. May. 2002;45(5):601-4. Case-series. [pmid: 12004207].
2241 Kennedy ML, Nguyen H, Lubowski DZ, et al. Stimulated gracilis neosphincter: a new procedure for anal incontinence. Aust N Z J Surg. Jun. 1996;66(6):353-7. Case-series. [pmid: 8678851].
2242 Kennelly MJ, Kang J. Botulinum-A toxin injections as a treatment for refractory detrusor hyperreflexia. Topics in Spinal Cord Injury Rehabilitation. Winter. 2003;8(3):46-53. Case-series.
2243 Kenton K, FitzGerald MP, Brubaker L. Multiple foreign body erosions after laparoscopic colposuspension with mesh. Am J Obstet Gynecol. Jul. 2002;187(1):252-3. Case-reports. [pmid: 12114923].
2244 Kenton K, Fitzgerald MP, Brubaker L. What is a clinician to do-believe the patient or her urinary diary?. J Urol. Aug. 2006;176(2):633-5. discussion 5. Not eligible outcomes. [pmid: 16813908].
2245 Kenton K, FitzGerald MP, Shott S, et al. Role of urethral electromyography in predicting outcome of Burch retropubic urethropexy. Am J Obstet Gynecol. Jul. 2001;185(1):51-5. Not eligible outcomes. [pmid: 11483903].
2246 Kenton K, Mahajan S, Fitzgerald MP, et al. Recurrent stress incontinence is associated with decreased neuromuscular function in the striated urethral sphincter. Am J Obstet Gynecol. May. 2006;194(5):1434-7. Not eligible outcomes. [pmid: 16579918].
2247 Kenton K, Mueller ER. The global burden of female pelvic floor disorders. BJU Int. Sep. 2006;98(Suppl 1):1-5. discussion 6–7. Comment. [pmid: 16911592].
2248 Kenton K, Oldham L, Brubaker L. Open Burch urethropexy has a low rate of perioperative complications. Am J Obstet Gynecol. Jul. 2002;187(1):107-10. Case-series. [pmid: 12114897].
2249 Keranen U, Luukkonen P, Jarvinen H. Functional results after restorative proctocolectomy complicated by pouchitis. Dis Colon Rectum. Jul. 1997;40(7):764-9. Case-series. [pmid: 9221849].
2250 Kerr LA, Zincke H. Radical retropubic prostatectomy for prostate cancer in the elderly and the young: complications and prognosis. Eur Urol. 1994;25(4):305-11. discussion 11–2. Not eligible outcomes. [pmid: 8056022].
2251 Kerschan-Schindl K, Uher E, Wiesinger G, et al. Reliability of pelvic floor muscle strength measurement in elderly incontinent women. Neurourol Urodyn. 2002;21(1):42-7. Not eligible outcomes. [pmid: 11835423].
2252 Kesarwani PK, Misra R, Goel A, et al. Vesicocervical fistula: an unusual complication of vesicovaginal [corrected] fistula repair. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):358-9. Case Reports. [pmid: 15580425].
2253 Keshtgar AS, Rickwood AM. Urological consequences of incomplete cord lesions in patients with myelomeningocele. Br J Urol. Aug. 1998;82(2):258-60. Not eligible target population. [pmid: 9722763].
2254 Kessler TM, Burkhard FC, Perimenis P, et al. Attempted nerve sparing surgery and age have a significant effect on urinary continence and erectile function after radical cystoprostatectomy and ileal orthotopic bladder substitution. J Urol. Oct. 2004;172(4 Pt 1):1323-7. Case-series. [pmid: 15371833].
2255 Kessler TM, Danuser H, Schumacher M, et al. Botulinum A toxin injections into the detrusor: an effective treatment in idiopathic and neurogenic detrusor overactivity?. Neurourol Urodyn. 2005;24(3):231-6. Not eligible target population. [pmid: 15747344].
2256 Kessler TM, Lackner J, Kiss G, et al. Predictive value of initial urodynamic pattern on urinary continence in patients with myelomeningocele. Neurourol Urodyn. 2006;25(4):361-7. Not eligible target population. [pmid: 16721816].
2257 Khadilkar S, Menezes K, Lele V, et al. Gelastic epilepsy—a case report with SPECT studies. J Assoc Physicians India. May. 2001;49:581-3. Case Reports. [pmid: 11361281].
2258 Khair B, Azmy AF, Carachi R, et al. Continent urinary diversion using Mitrofanoff principle in children with neurogenic bladder. Eur J Pediatr Surg. Dec. 1993;3(Suppl 1):8-9. Not eligible target population. [pmid: 8130157].
2259 Khalid U, McGough C, Hackett C, et al. A modified inflammatory bowel disease questionnaire and the Vaizey Incontinence questionnaire are more sensitive measures of acute gastrointestinal toxicity during pelvic radiotherapy than RTOG grading. Int J Radiat Oncol Biol Phys. Apr 1. 2006;64(5):1432-41. Not eligible outcomes. [pmid: 16580497].
2260 Khan MS, Chaliha C, Leskova L, et al. The relationship between urinary symptom questionnaires and urodynamic diagnoses: an analysis of two methods of questionnaire administration. Bjog. May. 2004;111(5):468-74. Not eligible level of evidence. [pmid: 15104612].
2261 Khanduja KS, Padmanabhan A, Kerner BA, et al. Reconstruction of rectovaginal fistula with sphincter disruption by combining rectal mucosal advancement flap and anal sphincteroplasty. Dis Colon Rectum. Nov. 1999;42(11):1432-7. Case-series. [pmid: 10566531].
2262 Khanduja KS, Yamashita HJ, Wise WE Jr, et al. Delayed repair of obstetric injuries of the anorectum and vagina. A stratified surgical approach. Dis Colon Rectum. Apr. 1994;37(4):344-9. Case-series. [pmid: 8168413].
2263 Kharrazi M, Kharrazi LD. Delayed diagnosis of cystic fibrosis and the family perspective. J Pediatr. Sep. 2005;147(3 Suppl):S21-5. Not eligible outcomes. [pmid: 16202777].
2264 Khorsandi M, Ginsberg PC, Harkaway RC. Reassessing the role of urodynamics after cerebrovascular accident. Males versus females. Urol Int. 1998;61(3):142-6. Not eligible target population. [pmid: 9933833].
2265 Khoury AE, Agarwal SK, Bagli D, et al. Concomitant modified bladder neck closure and Mitrofanoff urinary diversion. J Urol. Nov. 1999;162(5):1746-8. Case-series. [pmid: 10524928].
2266 Khoury JM, Webster GD, Perez LM. Urethral cuff erosion as a result of urinary catheterization in patients with an artificial urinary sphincter. N C Med J. May. 1994;55(5):162-4. Case Reports. [pmid: 8035884].
2267 Khullar V, Hill S, Laval KU, et al. Treatment of urge-predominant mixed urinary incontinence with tolterodine extended release: a randomized, placebo-controlled trial. Urology. Aug. 2004;64(2):269-74. discussion 74–5. Not eligible exposure. [pmid: 15302476].
2268 Kielb S, Dunn RL, Rashid MG, et al. Assessment of early continence recovery after radical prostatectomy: patient reported symptoms and impairment. J Urol. Sep. 2001;166(3):958-61. Case-series. [pmid: 11490254].
2269 Kielb SJ, Clemens JQ. Endoscopic excision of intravesical tension-free vaginal tape with laparoscopic instrument assistance. J Urol. Sep. 2004;172(3):971. Case Reports. [pmid: 15311012].
2270 Kielb SJ, Clemens JQ. Comprehensive urodynamics evaluation of 146 men with incontinence after radical prostatectomy. Urology. Aug. 2005;66(2):392-6. Case-series. [pmid: 16040102].
2271 Kienle P, Weitz J, Koch M, et al. Biofeedback versus electrostimulation in treatment of anal sphincter insufficiency. Dig Dis Sci. Aug. 2003;48(8):1607-13. Not eligible target population. [pmid: 12924655].
2272 Kilicarslan H, Gokce G, Ayan S, et al. Predictors of outcome after in situ anterior vaginal wall sling surgery. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):339-41. discussion 41. Case-series. [pmid: 14618312].
2273 Kilicarslan H, Guvenal T, Ayan S, et al. Comparison of outcomes of three different surgical techniques performed for stress urinary incontinence. Int J Urol. Mar. 2003;10(3):126-30. discussion 31. Case-series. [pmid: 12622706].
2274 Kim J. The development and evaluation of an incontinence intervention program for the elderly women at elderly welfare center. Taehan Kanho Hakhoe Chi. Dec. 2004;34(8):1427-33. Case-series. [pmid: 15687784].
2275 Kim J, Shim MC, Choi BY, et al. Clinical application of continent anal plug in bedridden patients with intractable diarrhea. Dis Colon Rectum. Aug. 2001;44(8):1162-7. Case-series. [pmid: 11535857].
2276 Kim JK, Kim YJ, Choo MS, et al. The urethra and its supporting structures in women with stress urinary incontinence: MR imaging using an endovaginal coil. AJR Am J Roentgenol. Apr. 2003;180(4):1037-44. Not eligible outcomes. [pmid: 12646452].
2277 Kim JS, Lee EH, Park HC. Urinary incontinence: prevalence and knowledge among community-dwelling Korean women aged 55 and over. Taehan Kanho Hakhoe Chi. Jun. 2004;34(4):609-16. Not eligible level of evidence. [pmid: 15502426].
2278 Kim KJ, Ashton-Miller JA, Strohbehn K, et al. The vesico-urethral pressuregram analysis of urethral function under stress. J Biomech. Jan. 1997;30(1):19-25. Not eligible outcomes. [pmid: 8970920].
2279 Kim NK, Lim DJ, Yun SH, et al. Ultralow anterior resection and coloanal anastomosis for distal rectal cancer: functional and oncological results. Int J Colorectal Dis. Aug. 2001;16(4):234-7. Case-series. [pmid: 11515683].
2280 Kim SH, Boye M, Bhattacharyya SK, et al. Medical visits among adults with symptoms commonly associated with an overactive bladder. BJU Int. Mar. 2006;97(3):551-4. Not eligible outcomes. [pmid: 16469024].
2281 Kim SM, Han SW, Choi SH. Left colonic antegrade continence enema: experience gained from 19 cases. J Pediatr Surg. Oct. 2006;41(10):1750-4. Case-series. [pmid: 17011282].
2282 Kim YH, Kattan MW, Boone TB. Correlation of urodynamic results and urethral coaptation with success after transurethral collagen injection. Urology. Dec. 1997;50(6):941-8. Case-series. [pmid: 9426727].
2283 Kim YT, Kwon DD, Kim J, et al. Gabapentin for overactive bladder and nocturia after anticholinergic failure. Int Braz J Urol. Jul–Aug. 2004;30(4):275-8. Case-series. [pmid: 15679954].
2284 Kincade JE, Dougherty MC, Busby-Whitehead J, et al. Self-monitoring and pelvic floor muscle exercises to treat urinary incontinence. Urol Nurs. Oct. 2005;25(5):353-63. No associative hypothesis tested. [pmid: 16294613].
2285 Kincade JE, Peckous BK, Busby-Whitehead J. A pilot study to determine predictors of behavioral treatment completion for urinary incontinence. Urol Nurs. Feb. 2001;21(1):39-44. Not eligible outcomes. [pmid: 11998114].
2286 Kinchen KS, Long S, Chang S, et al. The direct cost of stress urinary incontinence among women in a Medicaid population. Am J Obstet Gynecol. Dec. 2005;193(6):1936-44. Not eligible outcomes. [pmid: 16325594].
2287 Kinchen KS, Obenchain R, Swindle R. Impact of duloxetine on quality of life for women with symptoms of urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):337-44. Not eligible exposure. [pmid: 15662490].
2288 King JC, Currie DM, Wright E. Bowel training in spina bifida: importance of education, patient compliance, age, and anal reflexes. Arch Phys Med Rehabil. Mar. 1994;75(3):243-7. Not eligible target population. [pmid: 8129572].
2289 King JK, Freeman RM. Is antenatal bladder neck mobility a risk factor for postpartum stress incontinence?. Br J Obstet Gynaecol. Dec. 1998;105(12):1300-7. Not eligible level of evidence. [pmid: 9883922].
2290 Kingsley AN. Post traumatic anal incontinence. Nebr Med J. Dec. 1990;75(12):321-3. Case-series.
2291 Kinn AC. Burch colposuspension for stress urinary incontinence. 5-year results in 153 women. Scand J Urol Nephrol. Dec. 1995;29(4):449-55. Case-series. [pmid: 8719362].
2292 Kinn AC. Tension-free vaginal tape evaluated using patient self-reports and urodynamic testing—a two-year follow-up. Scand J Urol Nephrol. Dec. 2001;35(6):484-90. Case-series. [pmid: 11848428].
2293 Kinn AC, Larsson PO. Desmopressin: a new principle for symptomatic treatment of urgency and incontinence in patients with multiple sclerosis. Scand J Urol Nephrol. 1990;24(2):109-12. Not eligible exposure. [pmid: 2192444].
2294 Kinn AC, Nilsson BY. Urethral sensitivity in incontinent women. Eur Urol. Jul. 2005;48(1):116-20. Not eligible outcomes. [pmid: 15967260].
2295 Kinnunen O. Study of constipation in a geriatric hospital, day hospital, old people's home and at home. Aging (Milano). Jun. 1991;3(2):161-70. Not eligible outcomes. [pmid: 1911905].
2296 Kirchner R, Diaconescu MR. Management of perineal impalement injuries. Rev Med Chir Soc Med Nat Iasi. Jul–Dec. 1992;96(34):141-5. Case-series. [pmid: 1344845].
2297 Kirkeby LT, Beier-Holgersen R, Nordling J. Successful pregnancy after ileocystoplasty. Case report. Scand J Urol Nephrol. 1992;26(2):195. Case-reports. [pmid: 1626210].
2298 Kirkham AP, Knight SL, Craggs MD, et al. Neuromodulation through sacral nerve roots 2 to 4 with a Finetech-Brindley sacral posterior and anterior root stimulator. Spinal Cord. Jun. 2002;40(6):272-81. Case-series. [pmid: 12037708].
2299 Kirkland VL, Palmer MH, Fitzgerald ST. Incontinence in a manufacturing setting: women's perceptions and responses. Public Health Nurs. Sep–Oct. 2001;18(5):312-7. Not eligible level of evidence. [pmid: 11559414].
2300 Kirschner-Hermanns R, Wein B, Niehaus S, et al. The contribution of magnetic resonance imaging of the pelvic floor to the understanding of urinary incontinence. Br J Urol. Nov. 1993;72(5 Pt 2):715-8. Not eligible outcomes. [pmid: 8281401].
2301 Kirshblum SC, Gulati M, O'Connor KC, et al. Bowel care practices in chronic spinal cord injury patients. Arch Phys Med Rehabil. Jan. 1998;79(1):20-3. Not eligible outcomes. [pmid: 9440411].
2302 Kisli E, Kisli M, Agargun H, et al. Impaired function of the levator ani muscle in the grand multipara and great grand multipara. Tohoku J Exp Med. Dec. 2006;210(4):365-72. Not eligible outcomes. [pmid: 17146203].
2303 Kitamura H, Miyao N, Yanase M, et al. Quality of life in patients having an ileal conduit, continent reservoir or orthotopic neobladder after cystectomy for bladder carcinoma. Int J Urol. Aug. 1999;6(8):393-9. Case-series. [pmid: 10466451].
2304 Kives S, Delisle MF, Mitchell GW. Vesicouterine fistula in pregnancy: a case report. J Obstet Gynaecol Can. Jul. 2004;26(7):657-9. Case-reports. [pmid: 15248935].
2305 Kizilkaya Beji N, Yalcin O, Ayyildiz EH, et al. Effect of urinary leakage on sexual function during sexual intercourse. Urol Int. 2005;74(3):250-5. Not eligible outcomes. [pmid: 15812213].
2306 Kjerulff KH, Langenberg PW, Rhodes JC, et al. Effectiveness of hysterectomy. Obstet Gynecol. Mar. 2000;95(3):319-26. Not eligible outcomes. [pmid: 10711536].
2307 Kjolhede P. Genital prolapse in women treated successfully and unsuccessfully by the Burch colposuspension. Acta Obstet Gynecol Scand. Apr. 1998;77(4):444-50. Not eligible outcomes. [pmid: 9598956].
2308 Kjolhede P. Long-term efficacy of Burch colposuspension: a 14-year follow-up study. Acta Obstet Gynecol Scand. Aug. 2005;84(8):767-72. Case-series. [pmid: 16026403].
2309 Kjolhede P, Noren B, Ryden G. Prediction of genital prolapse after Burch colposuspension. Acta Obstet Gynecol Scand. Oct. 1996;75(9):849-54. Not eligible outcomes. [pmid: 8931511].
2310 Kjolhede P, Ryden G. Prognostic factors and long-term results of the Burch colposuspension. A retrospective study. Acta Obstet Gynecol Scand. Sep. 1994;73(8):642-7. Case-series. [pmid: 7941990].
2311 Kjolhede P, Ryden G. Clinical and urodynamic characteristics of women with recurrent urinary incontinence after Burch colposuspension. Acta Obstet Gynecol Scand. May. 1997;76(5):461-7. Case-series. [pmid: 9197450].
2312 Kjolhede P, Ryden G, Hewardt P. Abdominal urethrocystopexy using fibrin sealant. A prospective study of long-term efficacy. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(2):93-6. Case-series. [pmid: 10805266].
2313 Kjolhede P, Wahlstrom J, Wingren G. Pelvic floor dysfunction after Burch colposuspension—a comprehensive study. Part I. Acta Obstet Gynecol Scand. Sep. 2005;84(9):894-901. Not eligible level of evidence. [pmid: 16097983].
2314 Kjolseth D, Madsen B, Knudsen LM, et al. Biofeedback treatment of children and adults with idiopathic detrusor instability. Scand J Urol Nephrol. Sep. 1994;28(3):243-7. Not eligible target population. [pmid: 7817166].
2315 Klaphajone J, Kitisomprayoonkul W, Sriplakit S. Botulinum toxin type A injections for treating neurogenic detrusor overactivity combined with low-compliance bladder in patients with spinal cord lesions. Arch Phys Med Rehabil. Nov. 2005;86(11):2114-8. Not eligible target population. [pmid: 16271557].
2316 Klatka LA, Depper MH, Marini AM. Infarction in the territory of the anterior cerebral artery. Neurology. Aug. 1998;51(2):620-2. Case Reports. [pmid: 9710053].
2317 Klaus A, Hinder RA, DeVault KR, et al. Bowel dysfunction after laparoscopic antireflux surgery: incidence, severity, and clinical course. Am J Med. Jan. 2003;114(1):6-9. Case-series. [pmid: 12543282].
2318 Klauser A, Frauscher F, Strasser H, et al. Age-related rhabdosphincter function in female urinary stress incontinence: assessment of intraurethral sonography. J Ultrasound Med. May. 2004;23(5):631-7. quiz 8–9. Not eligible outcomes. [pmid: 15154529].
2319 Klausner TI. Urologic challenges in the menopausal woman: a case study. Urol Nurs. Aug. 2003;23(4):293-5. Case-reports. [pmid: 14552076].
2320 Klay M, Marfyak K. Use of a continence nurse specialist in an extended care facility. Urol Nurs 2005 Apr; 25(2):101–2, 7–8. Case-series
2321 Kleeman S, Goldwasser S, Vassallo B, et al. Predicting postoperative voiding efficiency after operation for incontinence and prolapse. Am J Obstet Gynecol. Jul. 2002;187(1):49-52. Not eligible exposure. [pmid: 12114887].
2322 Kleeman SD, Vasallo B, Segal J, et al. Vesicocervical fistula following insertion of a modified McDonald suture. Bjog. Dec. 2002;109(12):1408-9. Case Reports. [pmid: 12504981].
2323 Klein EA. Modified apical dissection for early continence after radical prostatectomy. Prostate. 1993;22(3):217-23. Case-series. [pmid: 8488154].
2324 Klein MC, Gauthier RJ, Jorgensen SH, et al. Does episiotomy prevent perineal trauma and pelvic floor relaxation? Online J Curr Clin Trials 1992 Jul 1; Doc No 10:[6019 words; 65 paragraphs]. Not eligible level of evidence
2325 Kleinhans B, Gerharz E, Melekos M, et al. Changes of urodynamic findings after radical retropubic prostatectomy. Eur Urol. 1999;35(3):217-21. discussion 21–2. Case-series. [pmid: 10072623].
2326 Klemm LW, Creason NS. Self-care practices of women with urinary incontinence—a preliminary study. Health Care Women Int. Apr–Jun. 1991;12(2):199-209. Case-series. [pmid: 2022530].
2327 Klijn AJ, Hop WC, Mickisch G, et al. The artificial urinary sphincter in men incontinent after radical prostatectomy: 5 year actuarial adequate function rates. Br J Urol. Oct. 1998;82(4):530-3. Case-series. [pmid: 9806182].
2328 Klimo P Jr, Rao G, Schmidt RH, et al. Nerve sheath tumors involving the sacrum. Case report and classification scheme. Neurosurg Focus. Aug 15. 2003;15(2):E12. Case Reports.
2329 Kling KM, Rongione AJ, Evans B, et al. The Delorme procedure: a useful operation for complicated rectal prolapse in the elderly. Am Surg. Oct. 1996;62(10):857-60. Case-series. [pmid: 8813171].
2330 Klingele CJ, Bharucha AE, Fletcher JG, et al. Pelvic organ prolapse in defecatory disorders. Obstet Gynecol. Aug. 2005;106(2):315-20. Not eligible outcomes. [pmid: 16055581].
2331 Klingele CJ, Carley ME, Hill RF. Patient characteristics that are associated with urodynamically diagnosed detrusor instability and genuine stress incontinence. Am J Obstet Gynecol. May. 2002;186(5):866-8. Not eligible target population. [pmid: 12015497].
2332 Klingler HC, Madersbacher S, Djavan B, et al. Morbidity of the evaluation of the lower urinary tract with transurethral multichannel pressure-flow studies. J Urol. Jan. 1998;159(1):191-4. Not eligible outcomes. [pmid: 9400470].
2333 Klingler HC, Pycha A, Schmidbauer J, et al. Use of peripheral neuromodulation of the S3 region for treatment of detrusor overactivity: a urodynamic-based study. Urology. Nov 1. 2000;56(5):766-71. Not eligible target population. [pmid: 11068296].
2334 Klutke CG, Nadler RB, Tiemann D, et al. Early results with antegrade collagen injection for post-radical prostatectomy stress urinary incontinence. J Urol. Nov. 1996;156(5):1703-6. Not eligible target population. [pmid: 8863575].
2335 Klutke CG, Tiemann DD, Nadler RB, et al. Antegrade collagen injection for stress incontinence after radical prostatectomy: technique and early results. J Endourol. Jun. 1996;10(3):279-82. Case-series. [pmid: 8740392].
2336 Klutke JJ, Bergman J, Klutke CG. Transvaginal bladder neck suspension with Cooper's ligament fixation. Long-term urodynamic results. J Reprod Med. Jul. 2000;45(7):541-5. Case-series. [pmid: 10948463].
2337 Klutke JJ, Klutke CG, Bergman J, et al. Bladder neck suspension for stress urinary incontinence: how does it work?. Neurourol Urodyn. 1999;18(6):623-7. Case-series. [pmid: 10529710].
2338 Klutke JJ, Klutke CG, Hsieh G. Bladder injury during the Burch retropubic urethropexy: is routine cystoscopy necessary?. Tech Urol. Sep. 1998;4(3):145-7. Case-series. [pmid: 9800893].
2339 Klutke JJ, Subir C, Andriole G, et al. Long-term results after antegrade collagen injection for stress urinary incontinence following radical retropubic prostatectomy. Urology. May. 1999;53(5):974-7. Not eligible target population. [pmid: 10223492].
2340 Knab K, Langhans B, Behrens R, et al. The neuropathic bowel in spina bifida—a cross-sectional study in 226 patients. Eur J Pediatr Surg. Dec. 2001;11(Suppl 1):S41-2. Not eligible target population. [pmid: 11848046].
2341 Knight J. Positive thinking. Nurs Stand. Feb 16–22. 2000;14(22):18-9. Comment. [pmid: 11310030].
2342 Knoefel WT, Hosch SB, Hoyer B, et al. The initial approach to anorectal abscesses: fistulotomy is safe and reduces the chance of recurrences. Dig Surg. 2000;17(3):274-8. Not eligible outcomes. [pmid: 10867462].
2343 Knoll M, Madersbacher H. The chances of a spina bifida patient becoming continent/socially dry by conservative therapy. Paraplegia. Jan. 1993;31(1):22-7. Not eligible target population. [pmid: 8446444].
2344 Knutson T, Edlund C, Fall M, et al. BPH with coexisting overactive bladder dysfunction—an everyday urological dilemma. Neurourol Urodyn. 2001;20(3):237-47. Not eligible target population. [pmid: 11385690].
2345 Knutson T, Pettersson S, Dahlstrand C. The use of biodegradable PGA stents to judge the risk of post-TURP incontinence in patients with combined bladder outlet obstruction and overactive bladder. Eur Urol. Sep. 2002;42(3):262-7. Case-series. [pmid: 12234511].
2346 Ko CY, Tong J, Lehman RE, et al. Biofeedback is effective therapy for fecal incontinence and constipation. Arch Surg. Aug. 1997;132(8):829-33. discussion 33–4. Case-series. [pmid: 9267265].
2347 Ko Y, Lin SJ, Salmon JW, et al. The impact of urinary incontinence on quality of life of the elderly. Am J Manag Care. Jul. 2005;11(4 Suppl):S103-11. Not eligible level of evidence. [pmid: 16161383].
2348 Kobak W, Lu J, Hardart A, et al. Expression of lysyl oxidase and transforming growth factor beta2 in women with severe pelvic organ prolapse. J Reprod Med. Nov. 2005;50(11):827-31. Not eligible outcomes. [pmid: 16419630].
2349 Kobashi KC, Govier FE. Perioperative complications: the first 140 polypropylene pubovaginal slings. J Urol. Nov. 2003;170(5):1918-21. Case-series. [pmid: 14532807].
2350 Kobashi KC, Leach GE, Chon J, et al. Continued multicenter followup of cadaveric prolapse repair with sling. J Urol. Nov. 2002;168(5):2063-8. Case-Series. [pmid: 12394709].
2351 Kobashi KC, Mee SL, Leach GE. A new technique for cystocele repair and transvaginal sling: the cadaveric prolapse repair and sling (CAPS). Urology. Dec 4. 2000;56(6 Suppl 1):9-14. Case-series.
2352 Kobata SA, Girao MJ, Sartori MG, et al. Urodynamic and ultrasonographic evaluation after continence surgery. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):321-4. Case-series. [pmid: 10543341].
2353 Kobelt G. Economic considerations and outcome measurement in urge incontinence. Urology. Dec. 1997;50(6A Suppl):100-7. discussion 8–10. Secondary data analysis.
2354 Kobelt G, Fianu-Jonasson A. Treatment of stress urinary incontinence with non-animal stabilised hyaluronic acid/dextranomer (NASHA/Dx) gel: An analysis of utility and cost. Clin Drug Investig. 2006;26(10):583-91. Not eligible outcomes.
2355 Koch SM, Uludag O, Rongen MJ, et al. Dynamic graciloplasty in patients born with an anorectal malformation. Dis Colon Rectum. Oct. 2004;47(10):1711-9. Case-series. [pmid: 15540304].
2356 Koch SM, van Gemert WG, Baeten CG. Determination of therapeutic threshold in sacral nerve modulation for faecal incontinence. Br J Surg. Jan. 2005;92(1):83-7. Case-series. [pmid: 15584063].
2357 Koch T, Kelly S. Identifying strategies for managing urinary incontinence with women who have multiple sclerosis. J Clin Nurs. Sep. 1999;8(5):550-9. Comment. [pmid: 10786527].
2358 Koch T, Kelly S. Understanding what is important for women who live with multiple sclerosis. Aust J Holist Nurs. Apr. 1999;6(1):14-24. Not eligible target population. [pmid: 11898197].
2359 Koch T, Kralik D. Chronic illness: reflections on a community-based action research programme. J Adv Nurs. Oct. 2001;36(1):23-31. Not associative hypothesis tested. [pmid: 11555046].
2360 Koch TR. Anal sphincter injury following forceps delivery. Am J Gastroenterol. Dec. 2003;98(12):2798-9. Comment. [pmid: 14717129].
2361 Kochakarn W. Tension-free vaginal tape procedure for the treatment of stress urinary incontinence: the first experience in Thailand. J Med Assoc Thai. Jan. 2002;85(1):87-91. Case-series. [pmid: 12075727].
2362 Kochakarn W, Leenanupunth C, Ratana-Olarn K, et al. Pubovaginal sling for the treatment of female stress urinary incontinence: experience of 100 cases at Ramathibodi Hospital. J Med Assoc Thai. Oct. 2001;84(10):1412-5. Case-series. [pmid: 11804250].
2363 Kochakarn W, Pummangura N, Kijvikai K, et al. Reliability of a Thai version of King's Health Questionnaire in Thai females with overactive bladder symptoms. J Med Assoc Thai. Nov. 2005;88(11):1526-34. Not eligible exposure. [pmid: 16471097].
2364 Kocjancic E, Tarrano E, Panella M, et al. Evaluation of minimally invasive analysis system for cough leak point pressure measurement. J Urol. Sep. 2004;172(3):994-7. Not eligible outcomes. [pmid: 15311021].
2365 Kocoglu H, Goksu S, Erbagci A, et al. Arterial blood gases in extraperitoneal laparoscopic urethrocystopexy. Int J Urol. Aug. 2002;9(8):422-6. Not eligible outcomes. [pmid: 12225337].
2366 Kodama H, Hieda I, Kuchinomachi Y, et al. Non-invasive ultrasonic urination sensor for ambulatory patient support. Methods Inf Med. Mar. 1994;33(1):97-100. No associative hypothesis tested. [pmid: 8177090].
2367 Koelbl H, Saz V, Doerfler D, et al. Transurethral injection of silicone microimplants for intrinsic urethral sphincter deficiency. Obstet Gynecol. Sep. 1998;92(3):332-6. Not eligible target population. [pmid: 9721765].
2368 Koelbl H, Stoerer S, Seliger G, et al. Transurethral penetration of a tension-free vaginal tape. Bjog. Jul. 2001;108(7):763-5. Case Reports. [pmid: 11467707].
2369 Koelle D, Stenzl A, Koelbl H, et al. Treatment of postoperative urinary retention by elongation of tension-free vaginal tape. Am J Obstet Gynecol. Jul. 2001;185(1):250-1. Case Reports. [pmid: 11483941].
2370 Koelle D, Windisch J, Doerfler D, et al. Effect of tension-free vaginal tape operation on urethral closure function. Urology. Mar. 2006;67(3):524-8. discussion 8–9. Case-series. [pmid: 16527571].
2371 Kohler A, Athanasiadis S. The value of posterior levator repair in the treatment of anorectal incontinence due to rectal prolapse—a clinical and manometric study. Langenbecks Arch Surg. Apr. 2001;386(3):188-92. Case-series. [pmid: 11382320].
2372 Kohler LW, Pemberton JH, Zinsmeister AR, et al. Quality of life after proctocolectomy. A comparison of Brooke ileostomy, Kock pouch, and ileal pouch-anal anastomosis. Gastroenterology. Sep. 1991;101(3):679-84. Not eligible level of evidence. [pmid: 1650316].
2373 Koivusalo A, Pakarinen M, Rintala RJ. Are cecal wrap and fixation necessary for antegrade colonic enema appendicostomy?. J Pediatr Surg. Feb. 2006;41(2):323-6. Not eligible target population. [pmid: 16481244].
2374 Koldewijn EL, Hommes OR, Lemmens WA, et al. Relationship between lower urinary tract abnormalities and disease-related parameters in multiple sclerosis. J Urol. Jul. 1995;154(1):169-73. Not eligible level of evidence. [pmid: 7539859].
2375 Kolligian ME, Palmer LS, Cheng EY, et al. Myofascial wrap to treat intractable urinary incontinence in children. Urology. Dec. 1998;52(6):1122-7. Not eligible target population. [pmid: 9836567].
2376 Kolominsky-Rabas PL, Hilz MJ, Neundoerfer B, et al. Impact of urinary incontinence after stroke: results from a prospective population-based stroke register. Neurourol Urodyn. 2003;22(4):322-7. Case Series. [pmid: 12808707].
2377 Komatsu J, Oya M, Ishikawa H. Quantitative assessment of anal canal sensation in patients undergoing low anterior resection for rectal cancer. Surg Today. 1995;25(10):867-73. Not eligible outcomes. [pmid: 8574052].
2378 Komolafe EO, Malomo AO, Ogunniyi A, et al. Shunt-responsive dementing illness in a Nigerian—a case report. West Afr J Med. Jun. 2003;22(2):197-8. Case- reports. [pmid: 14529237].
2379 Komorowski L, Chen B. Female urinary incontinence in China: experiences and perspectives. Health Care Women Int. Feb. 2006;27(2):169-81. Case-series. [pmid: 16484160].
2380 Konagaya M, Matsumoto A, Takase S, et al. Clinical analysis of longstanding subacute myelo-optico-neuropathy: sequelae of clioquinol at 32 years after its ban. J Neurol Sci. Mar 15. 2004;218(12):85-90. Not eligible target population. [pmid: 14759638].
2381 Kondo A. Status and tasks of today's urodynamics. Urol Int. 1991;47(Suppl 1):16-8. Secondary data analysis. [pmid: 1949373].
2382 Kondo A, Narushima M, Itoh Y, et al. Vaginal nylon sling: loop length and surgical outcomes in those with urethral hypermobility and intrinsic sphincter deficiency. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):182-7. Case-series. [pmid: 10430012].
2383 Kondo A, Yokoyama E, Koshiba K, et al. Bladder neck support prosthesis: a nonoperative treatment for stress or mixed urinary incontinence. J Urol. Mar. 1997;157(3):824-7. Not eligible target population. [pmid: 9072577].
2384 Kondo Y, Homma Y, Takahashi S, et al. Transvaginal ultrasound of urethral sphincter at the mid urethra in continent and incontinent women. J Urol. Jan. 2001;165(1):149-52. Not eligible level of evidence. [pmid: 11125385].
2385 Kondoh T, Amamoto N, Doi T, et al. Dramatic improvement in Down syndrome-associated cognitive impairment with donepezil. Ann Pharmacother. Mar. 2005;39(3):563-6. Case- Reports. [pmid: 15701776].
2386 Kong KH, Chan KF, Lim AC, et al. Detrusor hyperreflexia in strokes. Ann Acad Med Singapore. May. 1994;23(3):319-21. Case-series. [pmid: 7944241].
2387 Kong KH, Chua KS, Tow AP. Clinical characteristics and functional outcome of stroke patients 75 years old and older. Arch Phys Med Rehabil. Dec. 1998;79(12):1535-9. Case-series. [pmid: 9862295].
2388 Koninger JS, Butters M, Redecke JD, et al. Transverse coloplasty pouch after total mesorectal excision: functional assessment of evacuation. Dis Colon Rectum. Oct. 2004;47(10):1586-93. Case-series. [pmid: 15540285].
2389 Koninger JS, Butters M, Redecke JD, et al. Evacuation of neorectal reservoirs after TME. Recent Results Cancer Res. 2005;165:180-90. Case-series. [pmid: 15865032].
2390 Konsten J, Baeten CG, Den Dulk K, et al. Demonstration of the feasibility of implantation of a skeletal muscle pulse generator for fecal incontinence in a patient with an implanted unipolar DDD pacemaker. Pacing Clin Electrophysiol. May. 1992;15(5):825-30. Case- Reports. [pmid: 1382284].
2391 Konsten J, Baeten CG, Havenith MG, et al. Evaluation of gracilis muscle transposition for fecal incontinence with magnetic resonance imaging. Eur J Radiol. Apr. 1993;16(3):190-4. Case-series. [pmid: 8508833].
2392 Konsten J, Baeten CG, Spaans F, et al. Follow-up of anal dynamic graciloplasty for fecal continence. World J Surg. May–Jun. 1993;17(3):404-8. discussion 8–9. Case-series. [pmid: 8337888].
2393 Konsten J, Rongen MJ, Ogunbiyi OA, et al. Comparison of epineural or intramuscular nerve electrodes for stimulated graciloplasty. Dis Colon Rectum. Apr. 2001;44(4):581-6. Case-series. [pmid: 11330587].
2394 Kontturi MJ, Hellstrom PA, Tammela TL, et al. Colocystoplasty for the treatment of severe interstitial cystitis. Urol Int. 1991;46(1):50-4. Case-series. [pmid: 2024372].
2395 Koonings PP, Bergman A, Ballard CA. Prostaglandins for enhancing detrusor function after surgery for stress incontinence in women. J Reprod Med. Jan. 1990;35(1):1-5. Not eligible exposure. [pmid: 2299605].
2396 Koops SE, Bisseling TM, van Brummen HJ, et al. What determines a successful tension-free vaginal tape? A prospective multicenter cohort study: results from The Netherlands TVT database. Am J Obstet Gynecol. Jan. 2006;194(1):65-74. Not eligible exposure. [pmid: 16389011].
2397 Koraitim MM. On the art of anastomotic posterior urethroplasty: a 27-year experience. J Urol. Jan. 2005;173(1):135-9. Not eligible target population. [pmid: 15592055].
2398 Koraitim MM, Atta MA, Foda MK. Impact of the prostatic apex on continence and urinary flow in patients with intestinal neobladders. Br J Urol. Oct. 1996;78(4):534-6. Case-series. [pmid: 8944509].
2399 Korn AP, Learman LA. Operations for stress urinary incontinence in the United States, 1988-1992. Urology. Oct. 1996;48(4):609-12. Not eligible outcomes. [pmid: 8886068].
2400 Korsgen S, Deen KI, Keighley MR. Long-term results of total pelvic floor repair for postobstetric fecal incontinence. Dis Colon Rectum. Jul. 1997;40(7):835-9. Case-series. [pmid: 9221863].
2401 Korsgen S, Keighley MR. Stimulated gracilis neosphincter—not as good as previously thought. Report of four cases. Dis Colon Rectum. Dec. 1995;38(12):1331-3. Case Reports. [pmid: 7497849].
2402 Korzets A, Gepstein R, Ori Y, et al. Quadriparesis and faecal incontinence in a long-term haemodialysis patient. Nephrol Dial Transplant. Jan. 1997;12(1):224-5. Case Reports. [pmid: 9027808].
2403 Kossard S, Bear L. A florid papulo-nodular eruption in a sexagenarian. Australas J Dermatol. 1991;32(3):178-80. Case report. [pmid: 1823115].
2404 Kostov DV, Temelkov TD, Dragnev NA, et al. Smooth muscle sphincteroplasty in colostomy. Dis Colon Rectum. Apr. 2004;47(4):486-93. Case-series. [pmid: 14994111].
2405 Koyanagi T, Ameda K, Nantani M, et al. Preoperative cystometrography in patients with clinical benign prostatic hypertrophy. World J Urol. 1995;13(1):24-9. Case series. [pmid: 7539677].
2406 Koyle MA, Kaji DM, Duque M, et al. The Malone antegrade continence enema for neurogenic and structural fecal incontinence and constipation. J Urol. Aug. 1995;154(2 Pt 2):759-61. Not eligible target population. [pmid: 7609172].
2407 Kraemer M, Ho YH, Tan W. Effectiveness of anorectal biofeedback therapy for faecal incontinence: medium-term results. Tech Coloproctol. Dec. 2001;5(3):125-9. Case-series. [pmid: 11890160].
2408 Krahn M, Ritvo P, Irvine J, et al. Patient and community preferences for outcomes in prostate cancer: implications for clinical policy. Med Care. Jan. 2003;41(1):153-64. Case-series. [pmid: 12544552].
2409 Kralj B. Epidemiology of female urinary incontinence, classification of urinary incontinence, urinary incontinence in elderly women. Eur J Obstet Gynecol Reprod Biol. May 31. 1994;55(1):39-41. Review. [pmid: 7958139].
2410 Krauss JK, Droste DW, Vach W, et al. Cerebrospinal fluid shunting in idiopathic normal-pressure hydrocephalus of the elderly: effect of periventricular and deep white matter lesions. Neurosurgery. Aug. 1996;39(2):292-9. discussion 9–300. Case-series. [pmid: 8832666].
2411 Krauth JS, Rasoamiaramanana H, Barletta H, et al. Sub-urethral tape treatment of female urinary incontinence—morbidity assessment of the trans-obturator route and a new tape (I-STOP): a multi-centre experiment involving 604 cases. Eur Urol. Jan. 2005;47(1):102-6. discussion 6–7. Case-series. [pmid: 15582257].
2412 Kreder K, Das AK, Webster GD. The hemi-Kock ileocystoplasty: a versatile procedure in reconstructive urology. J Urol. May. 1992;147(5):1248-51. Case-series. [pmid: 1569660].
2413 Kreder KJ Jr, Brubaker L, Mainprize T. Tolterodine is equally effective in patients with mixed incontinence and those with urge incontinence alone. BJU Int. Sep. 2003;92(4):418-21. Not eligible exposure. [pmid: 12930432].
2414 Kreder KJ, Webster GD. Management of the bladder outlet in patients requiring enterocystoplasty. J Urol. Jan. 1992;147(1):38-41. Case-series. [pmid: 1729548].
2415 Kreis ME, Jehle EC, Haug V, et al. Functional results after transanal endoscopic microsurgery. Dis Colon Rectum. Oct. 1996;39(10):1116-21. Case-series. [pmid: 8831526].
2416 Kreis ME, Jehle EC, Ohlemann M, et al. Functional results after transanal rectal advancement flap repair of trans-sphincteric fistula. Br J Surg. Feb. 1998;85(2):240-2. Case-series. [pmid: 9501825].
2417 Krishna A, Gough DC, Fishwick J, et al. Ileocystoplasty in children: assessing safety and success. Eur Urol. 1995;27(1):62-6. Not eligible target population. [pmid: 7744145].
2418 Krissi H, Adam JE, Stanton SL. MRI visualization of the female pelvis in the plane of the tension-free vaginal tape (TVT) procedure. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):342-5. discussion 5–6. Not eligible outcomes. [pmid: 14618313].
2419 Krissi H, Pansky M, Halperin R, et al. Maximal urethral closure pressure < 20 cm H2O: does it predict intrinsic sphincteric deficiency?. J Reprod Med. Nov. 2005;50(11):824-6. Case-series. [pmid: 16419629].
2420 Kristiansson P, Samuelsson E, von Schoultz B, et al. Reproductive hormones and stress urinary incontinence in pregnancy. Acta Obstet Gynecol Scand. Dec. 2001;80(12):1125-30. Not eligible level of evidence. [pmid: 11846710].
2421 Krogh K, Christensen P, Sabroe S, et al. Neurogenic bowel dysfunction score. Spinal Cord. Oct. 2006;44(10):625-31. Not eligible outcomes. [pmid: 16344850].
2422 Krogh K, Laurberg S. Malone antegrade continence enema for faecal incontinence and constipation in adults. Br J Surg. Jul. 1998;85(7):974-7. Case-series. [pmid: 9692576].
2423 Krogh K, Nielsen J, Djurhuus JC, et al. Colorectal function in patients with spinal cord lesions. Dis Colon Rectum. Oct. 1997;40(10):1233-9. Not eligible target population. [pmid: 9336119].
2424 Kron M, Loy S, Sturm E, et al. Risk indicators for falls in institutionalized frail elderly. Am J Epidemiol. Oct 1. 2003;158(7):645-53. Not eligible outcomes. [pmid: 14507600].
2425 Krumholz HM, Chen J, Chen YT, et al. Predicting one-year mortality among elderly survivors of hospitalization for an acute myocardial infarction: results from the Cooperative Cardiovascular Project. J Am Coll Cardiol. Aug. 2001;38(2):453-9. Not eligible outcomes. [pmid: 11499737].
2426 Krupski TL, Saigal CS, Litwin MS. Variation in continence and potency by definition. J Urol. Oct. 2003;170(4 Pt 1):1291-4. Case series. [pmid: 14501744].
2427 Kruyt RH, Delemarre JB, Gooszen HG, et al. Defecography and anorectal manometry. Eur J Radiol. Sep. 1992;15(2):166-70. Not eligible outcomes. [pmid: 1425757].
2428 Krygowska-Wajs A, Hussey JM, Hulihan M, et al. Two large Polish kindreds with levodopa-responsive Parkinsonism not linked to known Parkinsonian genes and loci. Parkinsonism Relat Disord. Mar. 2003;9(4):193-200. Case- Reports. [pmid: 12618053].
2429 Ku JH, Jeong IG, Lim DJ, et al. Voiding diary for the evaluation of urinary incontinence and lower urinary tract symptoms: prospective assessment of patient compliance and burden. Neurourol Urodyn. 2004;23(4):331-5. Not eligible outcomes. [pmid: 15227650].
2430 Ku JH, Oh JG, Shin JW, et al. Outcome of mid-urethral sling procedures in Korean women with stress urinary incontinence according to body mass index. Int J Urol. Apr. 2006;13(4):379-84. Case-series. [pmid: 16734854].
2431 Ku JH, Oh JG, Shin JW, et al. Age is not a limiting factor for midurethral sling procedures in the elderly with urinary incontinence. Gynecol Obstet Invest. 2006;61(4):194-9. Case-series. [pmid: 16465064].
2432 Ku JH, Shin JW, Oh SJ, et al. Clinical and urodynamic features according to subjective symptom severity in female urinary incontinence. Neurourol Urodyn. 2006;25(3):215-20. Not eligible outcomes. [pmid: 16532459].
2433 Kubik K, Blackwell L, Heit M. Does socioeconomic status explain racial differences in urinary incontinence knowledge?. Am J Obstet Gynecol. Jul. 2004;191(1):188-93. Not eligible outcomes. [pmid: 15295363].
2434 Kuczyk MA, Klein S, Grunewald V, et al. A questionnaire-based outcome analysis of the Stamey bladder neck suspension procedure for the treatment of urinary stress incontinence: the Hannover experience. Br J Urol. Aug. 1998;82(2):174-80. Case-series. [pmid: 9722750].
2435 Kudo T, Mima T, Hashimoto R, et al. Tau protein is a potential biological marker for normal pressure hydrocephalus. Psychiatry Clin Neurosci. Apr. 2000;54(2):199-202. Not eligible outcomes. [pmid: 10803815].
2436 Kuehn BM. Silence masks prevalence of fecal incontinence. Jama. Mar 22. 2006;295(12):1362-3. News. [pmid: 16551705].
2437 Kuhn W, Rist M, Zaech GA. Intermittent urethral self-catheterisation: long term results (bacteriological evolution, continence, acceptance, complications). Paraplegia. May. 1991;29(4):222-32. Case-series. [pmid: 1870888].
2438 Kuijpers HC, Scheuer M. Disorders of impaired fecal control. A clinical and manometric study. Dis Colon Rectum. Mar. 1990;33(3):207-11. Not eligible outcomes. [pmid: 2311464].
2439 Kulkarni S, Davies AJ, Gowreeson G, et al. Flank abscess and bladder stone—late complications of permanent suture material used in colposuspension. J Obstet Gynaecol. Nov. 2004;24(8):938-9. Case Reports. [pmid: 16147668].
2440 Kuller JA, Katz VL, McCoy MC, et al. Pregnancy complicated by Guillain-Barre syndrome. South Med J. Sep. 1995;88(9):987-9. Case-reports. [pmid: 7660223].
2441 Kulseng-Hanssen S. The development of a national database of the results of surgery for urinary incontinence in women. BJOG. Nov. 2003;110(11):975-82. Not eligible outcomes. [pmid: 14592581].
2442 Kulseng-Hanssen S, S GH. Subjective and objective incontinence 5 to 10 years after Burch colposuspension. Neurourol Urodyn. 2002;21(2):100-5. Case-series. [pmid: 11857661].
2443 Kulseng-Hanssen S, Husby H, Schiotz HA. The tension free vaginal tape operation for women with mixed incontinence: Do preoperative variables predict the outcome?. Neurourol Urodyn. 2007;26(1):115-21. discussion 22. Case-series. [pmid: 16894616].
2444 Kumar D, Benson MJ, Bland JE. Glutaraldehyde cross-linked collagen in the treatment of faecal incontinence. Br J Surg. Jul. 1998;85(7):978-9. Case-series. [pmid: 9692577].
2445 Kumar D, Hutchinson R, Grant E. Bilateral gracilis neosphincter construction for treatment of faecal incontinence. Br J Surg. Dec. 1995;82(12):1645-7. Case-series. [pmid: 8548229].
2446 Kumar V, Toussi H, Marr C, et al. The benefits of radical prostatectomy beyond cancer control in symptomatic men with prostate cancer. BJU Int. Mar. 2004;93(4):507-9. Case-series. [pmid: 15008719].
2447 Kung RC, Lie K, Lee P, et al. The cost-effectiveness of laparoscopic versus abdominal Burch procedures in women with urinary stress incontinence. J Am Assoc Gynecol Laparosc. Aug. 1996;3(4):537-44. Case-series. [pmid: 9050685].
2448 Kuo HC. Transrectal sonography of the female urethra in incontinence and frequency-urgency syndrome. J Ultrasound Med. May. 1996;15(5):363-70. Not eligible outcomes. [pmid: 8731442].
2449 Kuo HC. Clinical outcome and quality of life after enterocystoplasty for contracted bladders. Urol Int. 1997;58(3):160-5. Case-series. [pmid: 9188137].
2450 Kuo HC. Transrectal sonographic investigation of urethral and paraurethral structures in women with stress urinary incontinence. J Ultrasound Med. May. 1998;17(5):311-20. Not eligible outcomes. [pmid: 9586704].
2451 Kuo HC. Quality of life after active urological management of chronic spinal cord injury in eastern Taiwan. Eur Urol. 1998;34(1):37-46. Not eligible target population.
2452 Kuo HC. Videourodynamic results after pubovaginal sling procedure for stress urinary incontinence. Urology. Nov. 1999;54(5):802-6. discussion 6–7. Case-series. [pmid: 10565737].
2453 Kuo HC. Sonographic evaluation of anatomic results after the pubovaginal sling procedure for stress urinary incontinence. J Ultrasound Med. Jul. 2001;20(7):739-47. Case-series. [pmid: 11444732].
2454 Kuo HC. Anatomical and functional results of pubovaginal sling procedure using polypropylene mesh for the treatment of stress urinary incontinence. J Urol. Jul. 2001;166(1):152-7. Not eligible target population. [pmid: 11435845].
2455 Kuo HC. Long-term results of surgical treatment for female stress urinary incontinence. Urol Int. 2001;66(1):13-7. Case-series. [pmid: 11150944].
2456 Kuo HC. Analysis of the pathophysiology of lower urinary tract symptoms in patients after prostatectomy. Urol Int. 2002;68(2):99-104. Case series. [pmid: 11834899].
2457 Kuo HC. Effectiveness of intravesical resiniferatoxin in treating detrusor hyper-reflexia and external sphincter dyssynergia in patients with chronic spinal cord lesions. BJU Int. Oct. 2003;92(6):597-601. Case-series. [pmid: 14511042].
2458 Kuo HC. Effectiveness of urethral injection of botulinum A toxin in the treatment of voiding dysfunction after radical hysterectomy. Urol Int. 2005;75(3):247-51. Case-series. [pmid: 16215314].
2459 Kuo HC. Clinical effects of suburothelial injection of botulinum A toxin on patients with nonneurogenic detrusor overactivity refractory to anticholinergics. Urology. Jul. 2005;66(1):94-8. Not eligible target population. [pmid: 15992869].
2460 Kuo HC, Chang SC, Hsu T. A new classification of female stress urinary incontinence—based on transrectal sonographic cystourethrography. J Formos Med Assoc. Aug. 1991;90(8):769-75. Case-series. [pmid: 1683371].
2461 Kuo HC, Liu HT, Yang WC. Therapeutic effect of multiple resiniferatoxin intravesical instillations in patients with refractory detrusor overactivity: a randomized, double-blind, placebo controlled study. J Urol. Aug. 2006;176(2):641-5. Not eligible exposure. [pmid: 16813911].
2462 Kupeli B, Kordan Y, Alkibay T. Urinary incontinence after pelvic trauma: a case report. Int Urol Nephrol. 2001;32(3):363-5. Case Reports. [pmid: 11583353].
2463 Kurabayashi H, Kubota K, Kawada E, et al. Complete cure of urinary and faecal incontinence after intravenous vitamin B12 therapy in a patient with post-gastrectomy megaloblastic anaemia. J Intern Med. Mar. 1992;231(3):313-5. Case- Reports. [pmid: 1556528].
2464 Kurfuerst S. Stop before it starts. Rehab Manag 2003 Oct; 16(8):42–4, 54. Comment
2465 Kursh ED. Factors influencing the outcome of a no incision endoscopic urethropexy. Surg Gynecol Obstet. Sep. 1992;175(3):254-8. Case-series. [pmid: 1514161].
2466 Kurzrock EA, Lowe P, Hardy BE. Bladder wall pedicle wraparound sling for neurogenic urinary incontinence in children. J Urol. Jan. 1996;155(1):305-8. Not eligible target population. [pmid: 7490876].
2467 Kushwaha RS, Hayne D, Vaizey CJ, et al. Physiologic changes of the anorectum after pelvic radiotherapy for the treatment of prostate and bladder cancer. Dis Colon Rectum. Sep. 2003;46(9):1182-8. Case-series. [pmid: 12972961].
2468 Kusunoki M, Okamoto T, Yoshikawa H, et al. Defecographic assessment after colonic J pouch-anal anastomosis. Surg Today. 1996;26(12):971-4. Case-series. [pmid: 9017957].
2469 Kusunoki M, Shoji Y, Ikeuchi H, et al. Usefulness of valproate sodium for treatment of incontinence after ileoanal anastomosis. Surgery. Mar. 1990;107(3):311-5. Not eligible target population. [pmid: 2106731].
2470 Kusunoki M, Shoji Y, Yanagi H, et al. Function after anoabdominal rectal resection and colonic J pouch—anal anastomosis. Br J Surg. Dec. 1991;78(12):1434-8. Case-series. [pmid: 1773317].
2471 Kuuva N, Nilsson CG. Tension-free vaginal tape procedure: an effective minimally invasive operation for the treatment of recurrent stress urinary incontinence?. Gynecol Obstet Invest. 2003;56(2):93-8. Case-series. [pmid: 12923350].
2472 Kuuva N, Nilsson CG. Long-term results of the tension-free vaginal tape operation in an unselected group of 129 stress incontinent women. Acta Obstet Gynecol Scand. 2006;85(4):482-7. Case-series. [pmid: 16612712].
2473 Kwon CH, Culligan PJ, Koduri S, et al. The development of pelvic organ prolapse following isolated Burch retropubic urethropexy. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):321-5. discussion 5. Case-series. [pmid: 14618308].
2474 Kwon E, Schulz JA, Flood CG. Success of pubovaginal sling in patients with stress urinary incontinence and efficacy of vaginal sling release in patients with post-sling voiding dysfunction. J Obstet Gynaecol Can. Jun. 2006;28(6):519-25. Case-series. [pmid: 16857120].
2475 Kylmala T, Tainio H, Raitanen M, et al. Treatment of postoperative male urinary incontinence using transurethral macroplastique injections. J Endourol. Mar. 2003;17(2):113-5. Case-series. [pmid: 12689406].
2476 Kylyc S, Sargin SY, Gunes A, et al. A rare condition: the ureteritis cystica. ScientificWorldJournal. Jun 7. 2004;4(Suppl 1):175-8. Case Reports. [pmid: 15349543].
2477 Kyne L, Merry C, O'Connell B, et al. Factors associated with prolonged symptoms and severe disease due to Clostridium difficile. Age Ageing. Mar. 1999;28(2):107-13. Not eligible target population. [pmid: 10350405].
2478 La Torre F, Masoni L, Montori J, et al. The surgical treatment of fecal incontinence with artificial anal sphincter implant. Preliminary clinical report. Hepatogastroenterology. Sep–Oct. 2004;51(59):1358-61. Case-series. [pmid: 15362752].
2479 Lachs MS, Feinstein AR, Cooney LM Jr, et al. A simple procedure for general screening for functional disability in elderly patients. Ann Intern Med. May 1. 1990;112(9):699-706. No associative hypothesis tested. [pmid: 2334082].
2480 Lacima G, Espuna M, Pera M, et al. Clinical, urodynamic, and manometric findings in women with combined fecal and urinary incontinence. Neurourol Urodyn. 2002;21(5):464-9. Not eligible outcomes. [pmid: 12232882].
2481 Lacima G, Pera M, Valls-Sole J, et al. Electrophysiologic studies and clinical findings in females with combined fecal and urinary incontinence: a prospective study. Dis Colon Rectum. Mar. 2006;49(3):353-9. Not eligible outcomes. [pmid: 16463137].
2482 Lacy BE, Zayat E, Crowell MD. Generalized intestinal dysmotility in a patient with syringomyelia. Am J Gastroenterol. Apr. 2001;96(4):1282-5. Case Reports. [pmid: 11316185].
2483 Lagerveld BW, Laguna MP, Debruyne FM, et al. Holmium:YAG laser for treatment of strictures of vesicourethral anastomosis after radical prostatectomy. J Endourol. May. 2005;19(4):497-501. Case-series. [pmid: 15910265].
2484 Lagro-Janssen AL, Debruyne FM, Van Weel C. Psychological aspects of female urinary incontinence in general practice. Br J Urol. Nov. 1992;70(5):499-502. Not eligible outcomes. [pmid: 1467853].
2485 Laguna MP, Brenninkmeier M, Belon JA, et al. Long-term functional and urodynamic results of 50 patients receiving a modified sigmoid neobladder created with a short distal segment. J Urol. Sep. 2005;174(3):963-7. Case-series. [pmid: 16094009].
2486 Lai HH, Hsu EI, Teh BS, et al. 13 years of experience with artificial urinary sphincter implantation at Baylor College of Medicine. J Urol. Mar. 2007;177(3):1021-5. Case-series. [pmid: 17296403].
2487 Lal R, Bhatnagar V, Agarwala S, et al. Urodynamic evaluation in boys treated for posterior urethral valves. Pediatr Surg Int. Jul. 1999;15(56):358-62. Not eligible target population. [pmid: 10415286].
2488 Lalos O, Berglund AL, Bjerle P. The long-term outcome of retropubic urethrocystopexy (sutures and fibrin sealant) and pubococcygeal repair. Acta Obstet Gynecol Scand. Feb. 2000;79(2):135-9. Case-series. [pmid: 10696962].
2489 Lalos O, Berglund AL, Lalos A. Impact of urinary and climacteric symptoms on social and sexual life after surgical treatment of stress urinary incontinence in women: a long-term outcome. J Adv Nurs. Feb. 2001;33(3):316-27. Case-series. [pmid: 11251718].
2490 Lalos O, Lalos A. Urinary, climacteric and sexual symptoms one year after treatment of endometrial and cervical cancer. Eur J Gynaecol Oncol. 1996;17(2):128-36. Case-series. [pmid: 8654469].
2491 Lam AM, Jenkins GJ, Hyslop RS. Laparoscopic Burch colposuspension for stress incontinence: preliminary results. Med J Aust. Jan 2. 1995;162(1):18-21. Not eligible outcomes. [pmid: 7845292].
2492 Lam GW, Foldspang A, Elving LB, et al. Social context, social abstention, and problem recognition correlated with adult female urinary incontinence. Dan Med Bull. Dec. 1992;39(6):565-70. Not eligible level of evidence. [pmid: 1468266].
2493 Lam SP, Fong SY, Kwok A, et al. Delayed neuropsychiatric impairment after carbon monoxide poisoning from burning charcoal. Hong Kong Med J. Dec. 2004;10(6):428-31. Case Reports. [pmid: 15591604].
2494 Lan Z, Jinghe L, Zhufeng L, et al. Comparison the efficiency of different surgical procedures for urinary stress incontinence. Chin Med Sci J. Jun. 2000;15(2):107-10. Case-series. [pmid: 12901635].
2495 Landi F, Cesari M, Onder G, et al. Indwelling urethral catheter and mortality in frail elderly women living in community. Neurourol Urodyn. 2004;23(7):697-701. Not eligible target population. [pmid: 15382190].
2496 Landi F, Onder G, Cesari M, et al. Functional decline in frail community-dwelling stroke patients. Eur J Neurol. Jan. 2006;13(1):17-23. Not eligible outcomes. [pmid: 16420389].
2497 Landis JR, Kaplan S, Swift S, et al. Efficacy of antimuscarinic therapy for overactive bladder with varying degrees of incontinence severity. J Urol. Feb. 2004;171(2 Pt 1):752-6. Not eligible exposure. [pmid: 14713803].
2498 Lang J, Zhu L, Sun Z, et al. Clinical study on collagen and stress urinary incontinence. Clin Exp Obstet Gynecol. 2002;29(3):180-2. Not eligible outcomes. [pmid: 12519037].
2499 Lang JH, Zhu L, Sun ZJ, et al. Estrogen levels and estrogen receptors in patients with stress urinary incontinence and pelvic organ prolapse. Int J Gynaecol Obstet. Jan. 2003;80(1):35-9. Not eligible outcomes. [pmid: 12527458].
2500 Lange V, Meyer G, Schardey HM, et al. Laparoscopic creation of a loop colostomy. J Laparoendosc Surg. Oct. 1991;1(5):307-12. Case Reports. [pmid: 1834285].
2501 Langebrekke A, Dahlstrom B, Eraker R, et al. The laparoscopic Burch procedure. A preliminary report. Acta Obstet Gynecol Scand. Feb. 1995;74(2):153-5. Case-series. [pmid: 7900513].
2502 Langer R, Golan A, Arad D, et al. Effects of induced menopause on Burch colposuspension for urinary stress incontinence. J Reprod Med. Dec. 1992;37(12):956-8. Not eligible target population. [pmid: 1287204].
2503 Langer R, Golan A, Neuman M, et al. The effect of large uterine fibroids on urinary bladder function and symptoms. Am J Obstet Gynecol. Oct. 1990;163(4 Pt 1):1139-41. Case-series. [pmid: 2145766].
2504 Langer R, Golan A, Ron-El R, et al. Colposuspension for urinary stress incontinence in premenopausal and postmenopausal women. Surg Gynecol Obstet. Jul. 1990;171(1):13-6. Case-series. [pmid: 2193412].
2505 Langer R, Lipshitz Y, Halperin R, et al. Long-Term (10–15 years) follow-up after Burch colposuspension for urinary stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(5):323-6. discussion 6–7. Not eligible target population. [pmid: 11715999].
2506 Lantzsch T, Goepel C, Wolters M, et al. Sacrospinous ligament fixation for vaginal vault prolapse. Arch Gynecol Obstet. Mar. 2001;265(1):21-5. Not eligible level of evidence. [pmid: 11327088].
2507 Lao TT, Halpern SH, MacDonald D, et al. Spinal subdural haematoma in a parturient after attempted epidural anaesthesia. Can J Anaesth. Apr. 1993;40(4):340-5. Case Reports. [pmid: 8485794].
2508 Lara LL, Troop PR, Beadleson-Baird M. The risk of urinary tract infection in bowel incontinent men. J Gerontol Nurs. May. 1990;16(5):24-6. Not eligible outcomes. [pmid: 2358644].
2509 Larsen WI, Yavorek TA. Pelvic organ prolapse and urinary incontinence in nulliparous women at the United States Military Academy. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):208-10. Not eligible level of evidence. [pmid: 16077995].
2510 Larson B, Collins A, Landgren BM. Urogenital and vasomotor symptoms in relation to menopausal status and the use of hormone replacement therapy (HRT) in healthy women during transition to menopause. Maturitas. Dec 15. 1997;28(2):99-105. Not eligible level of evidence. [pmid: 9522318].
2511 Larson DW, Chrouser K, Young-Fadok T, et al. Rectal complications after modern radiation for prostate cancer: a colorectal surgical challenge. J Gastrointest Surg. Apr. 2005;9(4):461-6. Case-series. [pmid: 15797224].
2512 LaSala CA. Incomplete bladder emptying after the tension-free vaginal tape procedure, necessitating release of the mesh. A report of three cases. J Reprod Med. May. 2003;48(5):387-90. Case Reports. [pmid: 12815916].
2513 LaSala CA, Schimpf MO, Udoh E, et al. Outcome of tension-free vaginal tape procedure when complicated by intraoperative cystotomy. Am J Obstet Gynecol. Dec. 2006;195(6):1857-61. Not eligible outcomes. [pmid: 17132487].
2514 Lasheen AE, Khalifa S, El Askry SM, et al. Closed rectopexy with transanal resection for complete rectal prolapse in adults. J Gastrointest Surg. Sep–Oct. 2005;9(7):980-4. Case-series. [pmid: 16137595].
2515 Lasser P, Dube P, Guillot JM, et al. Pseudocontinent perineal colostomy following abdominoperineal resection: technique and findings in 49 patients. Eur J Surg Oncol. Feb. 2001;27(1):49-53. Case-series. [pmid: 11237492].
2516 Latini JM, Alipour M, Kreder KJ Jr. Efficacy of sacral neuromodulation for symptomatic treatment of refractory urinary urge incontinence. Urology. Mar. 2006;67(3):550-3. discussion 3–4. Case-series. [pmid: 16527577].
2517 Laubach J. The problem of urinary incontinence in the elderly. N C Med J. Jan–Feb. 1999;60(1):42-5. Comment. [pmid: 9951288].
2518 Lauer D, Netsch D, Amick N. Product notebook: occlusive skin paste. Ostomy Wound Manage 1992 Sep; 38(7):20–2, 4, 6–8. Case- Reports
2519 Laurberg S, Swash M, Henry MM. Effect of postanal repair on progress of neurogenic damage to the pelvic floor. Br J Surg. May. 1990;77(5):519-22. Case-series. [pmid: 2354333].
2520 Laurikainen E, Kiilholma P. The tension-free vaginal tape procedure for female urinary incontinence without preoperative urodynamic evaluation. J Am Coll Surg. Apr. 2003;196(4):579-83. Case-series. [pmid: 12691935].
2521 Laurikainen E, Kiilholma P. A nationwide analysis of transvaginal tape release for urinary retention after tension-free vaginal tape procedure. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2006;17(2):111-9. Case-series. [pmid: 16132161].
2522 Laurikainen E, Rosti J, Pitkanen Y, et al. The Rosti sling: a new, minimally invasive, tension-free technique for the surgical treatment of female urinary incontinence-the first 217 patients. J Urol. Apr. 2004;171(4):1576-80. discussion 80. Case-series. [pmid: 15017224].
2523 Laurikkala J, Juhola M, Lammi S, et al. Analysis of the imputed female urinary incontinence data for the evaluation of expert system parameters. Comput Biol Med. Jul. 2001;31(4):239-57. Not eligible outcomes. [pmid: 11334634].
2524 Laurikkala J, Juhola M, Penttinen J, et al. Parameter evaluation of the differential diagnosis of female urinary incontinence for the construction of an expert system. Stud Health Technol Inform. 1997;43(Pt B):671-5. [pmid: 10179751].
2525 Law PA, Danin JC, Lamb GM, et al. Dynamic imaging of the pelvic floor using an open-configuration magnetic resonance scanner. J Magn Reson Imaging. Jun. 2001;13(6):923-9. Not eligible outcomes. [pmid: 11382954].
2526 Law PJ, Kamm MA, Bartram CI. A comparison between electromyography and anal endosonography in mapping external anal sphincter defects. Dis Colon Rectum. May. 1990;33(5):370-3. Not eligible outcomes. [pmid: 2183977].
2527 Law PJ, Kamm MA, Bartram CI. Anal endosonography in the investigation of faecal incontinence. Br J Surg. Mar. 1991;78(3):312-4. Not eligible outcomes. [pmid: 2021846].
2528 Law WL, Tung HM, Chu KW, et al. Ambulatory stapled haemorrhoidectomy: a safe and feasible surgical technique. Hong Kong Med J. Apr. 2003;9(2):103-7. Not eligible outcomes. [pmid: 12668820].
2529 Laycock J. Incontinence. Pelvic floor re-education. Nursing (Lond). Jul 25–Aug 21. 1991;4(39):15-7. Comment. [pmid: 1881640].
2530 Layward L, Holmes P. Research to combat urinary incontinence. Br J Community Nurs. Oct. 2006;11(10):433-6. Review. [pmid: 17167357].
2531 Lazorthes F, Gamagami R, Cabarrot P, et al. Is rectal intussusception a cause of idiopathic incontinence?. Dis Colon Rectum. May. 1998;41(5):602-5. Case-series. [pmid: 9593243].
2532 Lazzeri M, Calo G, Spinelli M, et al. Urodynamic effects of intravesical nociceptin/orphanin FQ in neurogenic detrusor overactivity: a randomized, placebo-controlled, double-blind study. Urology. May. 2003;61(5):946-50. Not eligible exposure. [pmid: 12736013].
2533 Le Lievre S. The management and prevention of incontinence dermatitis. Br J Community Nurs. Apr. 2001;6(4):180-5. Not eligible outcomes. [pmid: 11907443].
2534 Leach GE, Trockman B, Wong A, et al. Post-prostatectomy incontinence: urodynamic findings and treatment outcomes. J Urol. Apr. 1996;155(4):1256-9. Case-series. [pmid: 8632545].
2535 Leandri P, Rossignol G, Gautier JR, et al. Radical retropubic prostatectomy: morbidity and quality of life. Experience with 620 consecutive cases. J Urol. Mar. 1992;147(3 Pt 2):883-7. Case series. [pmid: 1538489].
2536 Leaver R, Pressland D. Intermittent self-catheterisation in urinary tract reconstruction. Br J Community Nurs. May. 2001;6(5):253-8. [pmid: 11893951].
2537 Leboeuf L, Mendez LE, Gousse AE. Small bowel obstruction associated with tension-free vaginal tape. Urology. Jun. 2004;63(6):1182-4. Case Reports.
2538 Lechaux JP, Atienza P, Goasguen N, et al. Prosthetic rectopexy to the pelvic floor and sigmoidectomy for rectal prolapse. Am J Surg. Nov. 2001;182(5):465-9. Case-series. [pmid: 11754852].
2539 Lechaux JP, Lechaux D, Perez M. Results of Delorme's procedure for rectal prolapse. Advantages of a modified technique. Dis Colon Rectum. Mar. 1995;38(3):301-7. Case-series. [pmid: 7882798].
2540 Leduc BE, Spacek E, Lepage Y. Colonic transit time after spinal cord injury: any clinical significance?. J Spinal Cord Med. Fall. 2002;25(3):161-6. Case-series. [pmid: 12214902].
2541 Lee AH, Somerford PJ, Yau KK. Factors influencing survival after stroke in Western Australia. Med J Aust. Sep 15. 2003;179(6):289-93. Not eligible level of evidence. [pmid: 12964910].
2542 Lee AH, Somerford PJ, Yau KK. Risk factors for ischaemic stroke recurrence after hospitalisation. Med J Aust. Sep 6. 2004;181(5):244-6. Not eligible outcomes. [pmid: 15347270].
2543 Lee CL, Yen CF, Wang CJ, et al. Trocar-assisted sling suspension for stress urinary incontinence. J Am Assoc Gynecol Laparosc. Nov. 2002;9(4):500-2. Case-series. [pmid: 12386363].
2544 Lee GY, Paradiso G, Tator CH, et al. Surgical management of tethered cord syndrome in adults: indications, techniques, and long-term outcomes in 60 patients. J Neurosurg Spine. Feb. 2006;4(2):123-31. Case-series. [pmid: 16506479].
2545 Lee HY, Lee SH, Kim SN. Castleman's disease: unusual case of inflammatory spinal dorsal epidural mass: case report. Neurosurgery. Feb. 2002;50(2):396-8. Case Reports. [pmid: 11852868].
2546 Lee IS, Choi ES. Pelvic floor muscle exercise by biofeedback and electrical stimulation to reinforce the pelvic floor muscle after normal delivery. Taehan Kanho Hakhoe Chi. Dec. 2006;36(8):1374-80. Not eligible target population. [pmid: 17215611].
2547 Lee JG, Hong JY, Choo MS, et al. Tolterodine: as effective but better tolerated than oxybutynin in Asian patients with symptoms of overactive bladder. Int J Urol. May. 2002;9(5):247-52. Not eligible exposure. [pmid: 12060436].
2548 Lee JY, Kim HW, Lee SJ, et al. Comparison of doxazosin with or without tolterodine in men with symptomatic bladder outlet obstruction and an overactive bladder. BJU Int. Oct. 2004;94(6):817-20. Case-series. [pmid: 15476515].
2549 Lee KS, Chan CJ, Merriman A, et al. Clinical profile of elderly urinary incontinence in Singapore: a community-based study. Ann Acad Med Singapore. Nov. 1991;20(6):736-9. Not eligible level of evidence. [pmid: 1803959].
2550 Lee KS, Choo MS, Kim DY, et al. Combination treatment with propiverine hydrochloride plus doxazosin controlled release gastrointestinal therapeutic system formulation for overactive bladder and coexisting benign prostatic obstruction: a prospective, randomized, controlled multicenter study. J Urol. Oct. 2005;174(4 Pt 1):1334-8. Not eligible outcomes. [pmid: 16145414].
2551 Lee KS, Han DH, Choi YS, et al. A prospective trial comparing tension-free vaginal tape and transobturator vaginal tape inside-out for the surgical treatment of female stress urinary incontinence: 1-year followup. J Urol. Jan. 2007;177(1):214-8. Not eligible target population. [pmid: 17162048].
2552 Lee KS, Owen RE, Choo PW, et al. Urinary incontinence in the elderly. Singapore Med J. Apr. 1991;32(2):161-3. No associative hypothesis tested. [pmid: 2042080].
2553 Lee KS, Owen RE, Choo PW, et al. Faecal incontinence in the elderly. Singapore Med J. Apr. 1991;32(2):164-5. [pmid: 2042081].
2554 Lee PS, Reid DW, Saltmarche A, et al. Measuring the psychosocial impact of urinary incontinence: the York Incontinence Perceptions Scale (YIPS). J Am Geriatr Soc. Nov. 1995;43(11):1275-8. Not eligible level of evidence. [pmid: 7594164].
2555 Lee SJ, Park YS. Serial evaluation of anorectal function following low anterior resection of the rectum. Int J Colorectal Dis. 1998;13(56):241-6. Case-series. [pmid: 9870169].
2556 Lee YH, Creasey GH. Self-controlled dorsal penile nerve stimulation to inhibit bladder hyperreflexia in incomplete spinal cord injury: a case report. Arch Phys Med Rehabil. Feb. 2002;83(2):273-7. Case- Reports. [pmid: 11833034].
2557 Lee YT, Cho TW, Jeong HS, et al. Reconfigured sigmoid colon neourethra: substitution of refractory posterior urethral stricture. Urology. Jan. 2005;65(1):157-9. Case Reports. [pmid: 15667883].
2558 Lefaucheur JP. Excitability of the motor cortical representation of the external anal sphincter. Exp Brain Res. Jan. 2005;160(2):268-72. Not eligible target population. [pmid: 15565435].
2559 Lefevre JH, Parc Y, Giraudo G, et al. Outcome of antegrade continence enema procedures for faecal incontinence in adults. Br J Surg. Oct. 2006;93(10):1265-9. Case-series. [pmid: 16952210].
2560 Leger JM, Henin D, Belec L, et al. Lymphoma-induced polyradiculopathy in AIDS: two cases. J Neurol. Mar. 1992;239(3):132-4. Not eligible exposure. [pmid: 1315382].
2561 Lehtoranta K, Tainio H, Lukkari-Lax E, et al. Pharmacokinetics, efficacy, and safety of intravesical formulation of oxybutynin in patients with detrusor overactivity. Scand J Urol Nephrol. Feb. 2002;36(1):18-24. Not eligible exposure. [pmid: 12002352].
2562 Lehur PA, Glemain P, Bruley des Varannes S, et al. Outcome of patients with an implanted artificial anal sphincter for severe faecal incontinence. A single institution report. Int J Colorectal Dis. 1998;13(2):88-92. Case-series. [pmid: 9638494].
2563 Lehur PA, Michot F, Denis P, et al. Results of artificial sphincter in severe anal incontinence. Report of 14 consecutive implantations. Dis Colon Rectum. Dec. 1996;39(12):1352-5. Case-series. [pmid: 8969659].
2564 Lehur PA, Roig JV, Duinslaeger M. Artificial anal sphincter: prospective clinical and manometric evaluation. Dis Colon Rectum. Aug. 2000;43(8):1100-6. Case-series. [pmid: 10950008].
2565 Lehur PA, Zerbib F, Neunlist M, et al. Comparison of quality of life and anorectal function after artificial sphincter implantation. Dis Colon Rectum. Apr. 2002;45(4):508-13. Not eligible target population. [pmid: 12006933].
2566 Leibovici D, Zisman A, Siegel YI, et al. Cryosurgical ablation for prostate cancer: preliminary results of a new advanced technique. Isr Med Assoc J. Jul. 2001;3(7):484-7. Case-series. [pmid: 11791412].
2567 Leiby DM, Shanahan N. Clinical study: assessing the performance and skin environments of two reusable underpads. Ostomy Wound Manage 1994 Oct; 40(8):30–2, 4–7. Not eligible outcomes
2568 Leighton JA, Valdovinos MA, Pemberton JH, et al. Anorectal dysfunction and rectal prolapse in progressive systemic sclerosis. Dis Colon Rectum. Feb. 1993;36(2):182-5. Case-series. [pmid: 8425423].
2569 Leissner J, Allhoff EP, Naumann G, et al. Inguinovaginal sling procedure for female stress incontinence: introduction of a minimally invasive technique. Tech Urol. Jun. 2001;7(2):105-9. Case-series. [pmid: 11383987].
2570 Lekan-Rutledge D. Behavioral vs drug treatment for urge urinary incontinence in older women: a randomized controlled trial. J Wound Ostomy Continence Nurs. May. 1999;26(3):27A-8A. Not eligible exposure.
2571 Lekan-Rutledge D. Diffusion of innovation. A model for implementation of prompted voiding in long-term care settings. J Gerontol Nurs. Apr. 2000;26(4):25-33. No associative hypothesis tested.
2572 Lekan-Rutledge D, Palmer MH, Belyea M. In their own words: nursing assistants' perceptions of barriers to implementation of prompted voiding in long-term care. Gerontologist. Jun. 1998;38(3):370-8. Not eligible target population. [pmid: 9640857].
2573 Lemack GE, Frohman EM, Zimmern PE, et al. Urodynamic distinctions between idiopathic detrusor overactivity and detrusor overactivity secondary to multiple sclerosis. Urology. May. 2006;67(5):960-4. Not eligible outcomes. [pmid: 16635509].
2574 Lemelle JL, Guillemin F, Aubert D, et al. A multicenter evaluation of urinary incontinence management and outcome in spina bifida. J Urol. Jan. 2006;175(1):208-12. Not eligible target population. [pmid: 16406913].
2575 Lemelle JL, Guillemin F, Aubert D, et al. A multicentre study of the management of disorders of defecation in patients with spina bifida. Neurogastroenterol Motil. Feb. 2006;18(2):123-8. Not eligible target population. [pmid: 16420290].
2576 Lemelle JL, Simo AK, Schmitt M. Comparative study of the Yang-Monti channel and appendix for continent diversion in the Mitrofanoff and Malone principles. J Urol. Nov. 2004;172(5 Pt 1):1907-10. Not eligible target population. [pmid: 15540752].
2577 Lemesh RA. Accidental chronic salicylate intoxication in an elderly patient: major morbidity despite early recognition. Vet Hum Toxicol. Feb. 1993;35(1):34-6. Case- Reports. [pmid: 8434448].
2578 Leng WW, Faerber G, Del Terzo M, et al. Long-term outcome of incontinent ileovesicostomy management of severe lower urinary tract dysfunction. J Urol. Jun. 1999;161(6):1803-6. Case-series. [pmid: 10332439].
2579 Lenihan JP, Palacios P, Sotomayor M. Oral and local anesthesia in the nonsurgical radiofrequency-energy treatment of stress urinary incontinence. J Minim Invasive Gynecol. Sep–Oct. 2005;12(5):415-9. Not eligible target population. [pmid: 16213427].
2580 Lentz SS, Homesley HD. Radiation-induced vesicosacral fistula: treatment with continent urinary diversion. Gynecol Oncol. Aug. 1995;58(2):278-80. Case- Reports. [pmid: 7622121].
2581 Leong AF, Yunos AB. Stoma management in a tropical country: colostomy irrigation versus natural evacuation. Ostomy Wound Manage. Nov. 1999;45(11):52-6. Case-series.
2582 Leonhardt C, Krysl J, Arenson AM, et al. Periurethral injection of collagen in the treatment of urinary stress incontinence: ultrasonographic appearance. Can Assoc Radiol J. Jun. 1995;46(3):189-93. Case-series. [pmid: 7538878].
2583 Lepisto A, Sarna S, Tiitinen A, et al. Female fertility and childbirth after ileal pouch-anal anastomosis for ulcerative colitis. Br J Surg. Apr. 2007;94(4):478-82. Not eligible outcomes. [pmid: 17310506].
2584 Lepisto M, Eriksson E, Hietanen H, et al. Developing a pressure ulcer risk assessment scale for patients in long-term care. Ostomy Wound Manage. Feb. 2006;52(2):34-46. Not eligible outcomes.
2585 Lepor H, Guerena M, Dixon CM. Perianastomotic injection of autologous fat at the time of radical retropubic prostatectomy. Urology. Nov. 1994;44(5):783-8. Case-series. [pmid: 7974959].
2586 Lepor H, Kaci L, Xue X. Continence following radical retropubic prostatectomy using self-reporting instruments. J Urol. Mar. 2004;171(3):1212-5. Not eligible outcomes. [pmid: 14767304].
2587 Lepor H, Nieder AM, Fraiman MC. Early removal of urinary catheter after radical retropubic prostatectomy is both feasible and desirable. Urology. Sep. 2001;58(3):425-9. Not eligible exposure. [pmid: 11549493].
2588 Lepor H, Theune C. Randomized double-blind study comparing the efficacy of terazosin versus placebo in women with prostatism-like symptoms. J Urol. Jul. 1995;154(1):116-8. Not eligible exposure. [pmid: 7776406].
2589 Lerner SE, Fleischmann J, Taub HC, et al. Combined laparoscopic pelvic lymph node dissection and modified belt radical perineal prostatectomy for localized prostatic adenocarcinoma. Urology. Apr. 1994;43(4):493-8. Case-series. [pmid: 8154070].
2590 Leroi AM, Dorival MP, Lecouturier MF, et al. Pudendal neuropathy and severity of incontinence but not presence of an anal sphincter defect may determine the response to biofeedback therapy in fecal incontinence. Dis Colon Rectum. Jun. 1999;42(6):762-9. Case-series. [pmid: 10378600].
2591 Leroi AM, Kamm MA, Weber J, et al. Internal anal sphincter repair. Int J Colorectal Dis. 1997;12(4):243-5. Case-series. [pmid: 9272456].
2592 Leroi AM, Michot F, Grise P, et al. Effect of sacral nerve stimulation in patients with fecal and urinary incontinence. Dis Colon Rectum. Jun. 2001;44(6):779-89. Not eligible target population. [pmid: 11391135].
2593 Leron E, Stanton SL. Vaginal leiomyoma—an imitator of prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2000;11(3):196-8. Case Reports. [pmid: 11484748].
2594 Leung HY, Yip SK, Cheon C, et al. A randomized controlled trial of tolterodine and oxybutynin on tolerability and clinical efficacy for treating Chinese women with an overactive bladder. BJU Int. Sep. 2002;90(4):375-80. Not eligible exposure. [pmid: 12175392].
2595 Lev N, Maimon S, Rappaport ZH, et al. Spinal dural arteriovenous fistulae—a diagnostic challenge. Isr Med Assoc J. Jul. 2001;3(7):492-6. Case-series. [pmid: 11791414].
2596 Levin I, Groutz A, Gold R, et al. Surgical complications and medium-term outcome results of tension-free vaginal tape: a prospective study of 313 consecutive patients. Neurourol Urodyn. 2004;23(1):7-9. Not eligible target population. [pmid: 14694449].
2597 Levitt MA, Soffer SZ, Pena A. Continent appendicostomy in the bowel management of fecally incontinent children. J Pediatr Surg. Nov. 1997;32(11):1630-3. Not eligible target population. [pmid: 9396543].
2598 Levitt MD, Kamm MA, Groom J, et al. Ileoanal pouch compliance and motor function. Br J Surg. Feb. 1992;79(2):126-8. Case-series. [pmid: 1555058].
2599 Levy BJ, Wight TN. Structural changes in the aging submucosa: new morphologic criteria for the evaluation of the unstable human bladder. J Urol. Oct. 1990;144(4):1044-55. Not eligible outcomes. [pmid: 2398553].
2600 Levy-Storms L, Schnelle JF, Simmons SF. What do family members notice following an intervention to improve mobility and incontinence care for nursing home residents? An analysis of open-ended comments. Gerontologist. Feb. 2007;47(1):14-20. Not eligible outcomes. [pmid: 17327536].
2601 Lewicky CE, Valentin C, Saclarides TJ. Sexual function following sphincteroplasty for women with third- and fourth-degree perineal tears. Dis Colon Rectum. Oct. 2004;47(10):1650-4. Case-series. [pmid: 15540294].
2602 Lewis CM, Schrader R, Many A, et al. Diabetes and urinary incontinence in 50- to 90-year-old women: a cross-sectional population-based study. Am J Obstet Gynecol. Dec. 2005;193(6):2154-8. Not eligible level of evidence. [pmid: 16325633].
2603 Lewis WG, Holdsworth PJ, Sagar PM, et al. Coordinated activity of the new “rectum” and anal sphincter after sphincter-saving resection of the rectum for colitis or carcinoma. Dis Colon Rectum. Oct. 1994;37(10):1012-9. [pmid: 7924707].
2604 Lewis WG, Martin IG, Williamson ME, et al. Why do some patients experience poor functional results after anterior resection of the rectum for carcinoma?. Dis Colon Rectum. Mar. 1995;38(3):259-63. Not eligible outcomes. [pmid: 7882788].
2605 Lewis WG, Miller AS, Williamson ME, et al. The perfect pelvic pouch—what makes the difference?. Gut. Oct. 1995;37(4):552-6. Case-series. [pmid: 7489944]. [pmcid: 1382909].
2606 Lewis-Abney K, Rosenkranz CF. Content validation of impaired skin integrity and urinary incontinence in the home health setting. Nurs Diagn. Jan–Mar. 1994;5(1):36-42. Question 4. [pmid: 8192950].
2607 Lewis-Byers K, K D. An evaluation of two incontinence skin care protocols in a long-term care setting. Ostomy Wound Manage. Dec. 2002;48(12):44-51. Not eligible outcomes.
2608 Li FL, Low LP, Lee DT. Chinese women's experiences in coping with urinary incontinence. J Clin Nurs. Mar. 2007;16(3):610-2. Case-series. [pmid: 17335537].
2609 Li YW, Hung WT, Chen CC, et al. Postoperative MRI of anorectal malformation. J Formos Med Assoc. Mar. 1997;96(3):199-204. Case-series. [pmid: 9080759].
2610 Liang CC, Chang SD, Chang YL, et al. Three-dimensional power Doppler measurement of perfusion of the periurethral tissue in incontinent women — a preliminary report. Acta Obstet Gynecol Scand. 2006;85(5):608-13. Not eligible outcomes. [pmid: 16752242].
2611 Liang CC, Chang YL, Chang SD, et al. Pessary test to predict postoperative urinary incontinence in women undergoing hysterectomy for prolapse. Obstet Gynecol. Oct. 2004;104(4):795-800. Not eligible exposure. [pmid: 15458904].
2612 Liang HM, Huang KH, Kung FT, et al. Combination of a tension-free vaginal tape procedure and laparoscopic-assisted vaginal hysterectomy for the treatment of benign uterine disease associated with stress urinary incontinence. Chang Gung Med J. Mar. 2005;28(3):166-73. Case-series. [pmid: 15945323].
2613 Liao YM, Dougherty MC, Liou YS, et al. Pelvic floor muscle training effect on urinary incontinence knowledge, attitudes, and severity: an experimental study. Int J Nurs Stud. Jan. 2006;43(1):29-37. Case-series. [pmid: 16326162].
2614 Liapis A, Bakas P, Creatsas G. Management of stress urinary incontinence in women with the use of tension-free vaginal tape. Eur Urol. Nov. 2001;40(5):548-51. Case-series. [pmid: 11752864].
2615 Liapis A, Bakas P, Pafiti A, et al. Changes of collagen type III in female patients with genuine stress incontinence and pelvic floor prolapse. Eur J Obstet Gynecol Reprod Biol. Jul. 2001;97(1):76-9. Not eligible outcomes. [pmid: 11435014].
2616 Liapis A, Bakas P, Pafiti A, et al. Changes in the quantity of collagen type I in women with genuine stress incontinence. Urol Res. Oct. 2000;28(5):323-6. Not eligible outcomes. [pmid: 11127711].
2617 Liapis A, Bakas P, Salamalekis E, et al. Tension-free vaginal tape (TVT) in women with low urethral closure pressure. Eur J Obstet Gynecol Reprod Biol. Sep 10. 2004;116(1):67-70. Case-series. [pmid: 15294371].
2618 Liapis A, Papoulias I, Chryssicopoulos A, et al. Results of the colposuspension operation in pre and postmenopausal incontinent women. Maturitas. Nov 30. 1998;31(1):69-75. Case-series. [pmid: 10091207].
2619 Liapis AH, Kalovidoyris A, Logis CD, et al. Transvaginal sonography in the postoperative evaluation of colposuspension. J Gynecol Surg. Fall. 1993;9(3):155-9. Case-series. [pmid: 10146411].
2620 Liberman H, Faria J, Ternent CA, et al. A prospective evaluation of the value of anorectal physiology in the management of fecal incontinence. Dis Colon Rectum. Nov. 2001;44(11):1567-74. Not eligible outcomes. [pmid: 11711725].
2621 Licht MR, Klein EA, Tuason L, et al. Impact of bladder neck preservation during radical prostatectomy on continence and cancer control. Urology. Dec. 1994;44(6):883-7. Case-series. [pmid: 7527169].
2622 Lieb J, Das AK. Urethral erosion of tension-free vaginal tape. Scand J Urol Nephrol. 2003;37(2):184-5. Case Reports. [pmid: 12745732].
2623 Lieu PK, Chia HH, Heng LC, et al. Carer-assisted intermittent urethral catheterisation in the management of persistent retention of urine in elderly women. Ann Acad Med Singapore. Jul. 1996;25(4):562-5. Case-series. [pmid: 8893931].
2624 Light JK, Marks JL. Total bladder replacement in the male and female using the ileocolonic segment (LeBag). Br J Urol. May. 1990;65(5):467-72. Case-series. [pmid: 2354312].
2625 Lii FN, Chen YM, Shu CH, et al. Metastatic nasopharyngeal carcinoma with epidural spinal cord compression: report of an unusual and catastrophic event. Zhonghua Yi Xue Za Zhi (Taipei). Feb. 1995;55(2):195-8. Case- Reports. [pmid: 7750063].
2626 Lilleby W, Fossa SD, Waehre HR, et al. Long-term morbidity and quality of life in patients with localized prostate cancer undergoing definitive radiotherapy or radical prostatectomy. Int J Radiat Oncol Biol Phys. Mar 1. 1999;43(4):735-43. Case series. [pmid: 10098428].
2627 Lilli P, Mercuriali M, Fiori M, et al. Impact of preoperative biofeedback on incontinence in cancer patients undergoing radical prostatectomy. Arch Ital Urol Androl. Sep. 2006;78(3):92-6. Not eligible target population. [pmid: 17137022].
2628 Liloku RB, Mure PY, Braga L, et al. The left Monti-Malone procedure: Preliminary results in seven cases. J Pediatr Surg. Feb. 2002;37(2):228-31. Case-series. [pmid: 11819204].
2629 Lim AG, Langmead FL, Feakins RM, et al. Diversion colitis: a trigger for ulcerative colitis in the in-stream colon?. Gut. Feb. 1999;44(2):279-82. Case Reports. [pmid: 9895391]. [pmcid: 1727389].
2630 Lim AJ, Brandon AH, Fiedler J, et al. Quality of life: radical prostatectomy versus radiation therapy for prostate cancer. J Urol. Oct. 1995;154(4):1420-5. Not eligible level of evidence. [pmid: 7658548].
2631 Lim HJ, Lee MS, Lee MS. Relation of urinary incontinence, menopausal symptoms, and life satisfaction in middle-age Korean women. Psychol Rep. Aug. 2005;97(1):203-4. Not eligible level of evidence. [pmid: 16279326].
2632 Lim JF, Ho YH. Total colectomy with ileorectal anastomosis leads to appreciable loss in quality of life irrespective of primary diagnosis. Tech Coloproctol. Aug. 2001;5(2):79-83. Case-series. [pmid: 11862562].
2633 Lim JF, Tjandra JJ, Hiscock R, et al. Preoperative chemoradiation for rectal cancer causes prolonged pudendal nerve terminal motor latency. Dis Colon Rectum. Jan. 2006;49(1):12-9. Case-series. [pmid: 16292664].
2634 Lim PP, Sahadevan S, Choo GK, et al. Burden of caregiving in mild to moderate dementia: an Asian experience. Int Psychogeriatr. Dec. 1999;11(4):411-20. Not eligible target population. [pmid: 10631586].
2635 Lim YN, Rane A. Suburethral vaginal erosion and pyogenic granuloma formation: an unusual complication of intravaginal slingplasty (IVS). Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):56-8. Case Reports. [pmid: 14752602].
2636 Lima SV, Araujo LA, Vilar FO. Nonsecretory intestinocystoplasty: a 10-year experience. J Urol. Jun. 2004;171(6 Pt 2):2636-39. discussion 9–40. Not eligible target population. [pmid: 15118439].
2637 Lima SV, Araujo LA, Vilar FO, et al. Combined use of enterocystoplasty and a new type of artificial sphincter in the treatment of urinary incontinence. J Urol. Aug. 1996;156(2 Pt 2):622-4. Not eligible target population. [pmid: 8683745].
2638 Limb J, Wood K, Weinberger M, et al. Sacral colpopexy using mersilene mesh in the treatment of vaginal vault prolapse. World J Urol. Feb. 2005;23(1):55-60. Case-series. [pmid: 15770518].
2639 Lin AT, Wang SJ, Chen KK, et al. In vivo tension sustained by fascial sling in pubovaginal sling surgery for female stress urinary incontinence. J Urol. Mar. 2005;173(3):894-7. Case-series. [pmid: 15711313].
2640 Lin CC, Bai YM, Chen JY, et al. A retrospective study of clozapine and urinary incontinence in Chinese in-patients. Acta Psychiatr Scand. Aug. 1999;100(2):158-61. Case-series. [pmid: 10480202].
2641 Lin DW, Santucci RA, Mayo ME, et al. Urodynamic evaluation and long-term results of the orthotopic gastric neobladder in men. J Urol. Aug. 2000;164(2):356-9. Case-series. [pmid: 10893584].
2642 Lin HH, Sheu BC, Lo MC, et al. Abnormal urodynamic findings after radical hysterectomy or pelvic irradiation for cervical cancer. Int J Gynaecol Obstet. Nov. 1998;63(2):169-74. Case-series. [pmid: 9856324].
2643 Lin HH, Torng PL, Sheu BC, et al. Urodynamically age-specific prevalence of urinary incontinence in women with urinary symptoms. Neurourol Urodyn. 2003;22(1):29-32. Not eligible target population. [pmid: 12478598].
2644 Lin HH, Yu HJ, Sheu BC, et al. Importance of urodynamic study before radical hysterectomy for cervical cancer. Gynecol Oncol. May. 2001;81(2):270-2. Not eligible level of evidence. [pmid: 11330961].
2645 Lin LY, Yeh NH, Lin CY, et al. Comparisons of urodynamic characteristics between female patients with overactive bladder and overactive bladder plus stress urinary incontinence. Urology. Nov. 2004;64(5):945-9. Not eligible outcomes. [pmid: 15533483].
2646 Lin SY, Dougherty MC. Incontinence impact, symptom distress and treatment-seeking behavior in women with involuntary urine loss in Southern Taiwan. Int J Nurs Stud. Mar. 2003;40(3):227-34. Not eligible outcomes. [pmid: 12605945].
2647 Lin YH, Liang CC, Lo TS, et al. Concomitant tension-free vaginal tape for urinary incontinence during laparoscopic hysterectomy. Aust N Z J Obstet Gynaecol. Aug. 2005;45(4):304-7. Case-series. [pmid: 16029297].
2648 Lindboe CF, Stolt-Nielsen A, Dale LG. Hemorrhage in a highly vascularized subependymoma of the septum pellucidum: case report. Neurosurgery. Oct. 1992;31(4):741-5. Case Reports. [pmid: 1407461].
2649 Lindesay J, Matthews R, Jagger C. Factors associated with antipsychotic drug use in residential care: changes between 1990 and 1997. Int J Geriatr Psychiatry. Jun. 2003;18(6):511-9. Not eligible outcomes. [pmid: 12789672].
2650 Lindsay J, Sykes E, McDowell I, et al. More than the epidemiology of Alzheimer's disease: contributions of the Canadian Study of Health and Aging. Can J Psychiatry. Feb. 2004;49(2):83-91. Not eligible outcomes. [pmid: 15065741].
2651 Lindsay R, James EL, Kippen S. The Timed Up and Go Test: unable to predict falls on the acute medical ward. Aust J Physiother. 2004;50(4):249-51. Not eligible outcomes. [pmid: 15574114].
2652 Lindsey I, Jones OM, Smilgin-Humphreys MM, et al. Patterns of fecal incontinence after anal surgery. Dis Colon Rectum. Oct. 2004;47(10):1643-9. Case-series. [pmid: 15540293].
2653 Link RE, Su LM, Bhayani SB, et al. Laparoscopic sacral colpoperineopexy for treatment of perineal body descent and vaginal vault prolapse. Urology. Jul. 2004;64(1):145-7. Case Reports. [pmid: 15245953].
2654 Linkletter D. No more surgery—biofeedback for continence. Ostomy Wound Manage. Nov–Dec. 1997;43(10):50-2. Comment. [pmid: 9460434].
2655 Lionis C, Vlachonikolis L, Bathianaki M, et al. Urinary incontinence, the hidden health problem of Cretan women: report from a primary care survey in Greece. Women Health. 2000;31(4):59-66. Not eligible level of evidence. [pmid: 11310811].
2656 Liptak GS, Revell GM. Management of bowel dysfunction in children with spinal cord disease or injury by means of the enema continence catheter. J Pediatr. Feb. 1992;120(2 Pt 1):190-4. Not eligible target population. [pmid: 1735813].
2657 Lipton RB, Kolodner K, Wesnes K. Assessment of cognitive function of the elderly population: effects of darifenacin. J Urol. Feb. 2005;173(2):493-8. Not eligible exposure. [pmid: 15643227].
2658 Liratzopoulos N, Efremidou EI, Papageorgiou MS, et al. Lateral subcutaneous internal sphincterotomy in the treatment of chronic anal fissure: our experience. J Gastrointestin Liver Dis. Jun. 2006;15(2):143-7. Case-series. [pmid: 16802009].
2659 Little JS Jr, Bihrle R, Foster RS. Early urethral catheter removal following radical prostatectomy: a pilot study. Urology. Sep. 1995;46(3):429-31. Case-series. [pmid: 7660526].
2660 Litwiller SE, Kim KB, Fone PD, et al. Post-prostatectomy incontinence and the artificial urinary sphincter: a long-term study of patient satisfaction and criteria for success. J Urol. Dec. 1996;156(6):1975-80. Case-series. [pmid: 8911369].
2661 Liu S, Christmas TJ, Nagendran K, et al. Sphincter electromyography in patients after radical prostatectomy and cystoprostatectomy. Br J Urol. Apr. 1992;69(4):397-403. Question 4. [pmid: 1581811].
2662 Lo TS, Chang TC, Chao AS, et al. Tension-free vaginal tape procedure on genuine stress incontinent women with coexisting genital prolapse. Acta Obstet Gynecol Scand. Nov. 2003;82(11):1049-53. Case-series. [pmid: 14616280].
2663 Lo TS, Horng SG, Chang CL, et al. Tension-free vaginal tape procedure after previous failure in incontinence surgery. Urology. Jul. 2002;60(1):57-61. Case-series.
2664 Lo TS, Horng SG, Liang CC, et al. Ultrasound and urodynamic comparison between caudocranial and craniocaudal tension-free vaginal tape for stress urinary incontinence. Urology. Oct. 2005;66(4):754-8. discussion 8–9. Case-series. [pmid: 16230131].
2665 Lo TS, Horng SG, Liang CC, et al. Ultrasound assessment of mid-urethra tape at three-year follow-up after tension-free vaginal tape procedure. Urology. Apr. 2004;63(4):671-5. Case-series. [pmid: 15072876].
2666 Lo TS, Huang HJ, Chang CL, et al. Use of intravenous anesthesia for tension-free vaginal tape therapy in elderly women with genuine stress incontinence. Urology. Mar. 2002;59(3):349-53. Case-series. [pmid: 11880068].
2667 Lo TS, Lee SJ. Treatment of recurrent genuine stress incontinence by shortening previously implanted tension-free vaginal tape. Acta Obstet Gynecol Scand. Oct. 2004;83(10):1005-6. Case Reports. [pmid: 15453904].
2668 Lo TS, Lin CT, Huang HJ, et al. The use of general anesthesia for the tension-free vaginal tape procedure and concomitant surgery. Acta Obstet Gynecol Scand. Apr. 2003;82(4):367-73. Case-series. [pmid: 12716322].
2669 Lo TS, Wang AC, Horng SG, et al. Ultrasonographic and urodynamic evaluation after tension free vagina tape procedure (TVT). Acta Obstet Gynecol Scand. Jan. 2001;80(1):65-70. Case-series. [pmid: 11167192].
2670 Lo TS, Wang AC, Liang CC, et al. Treatment for unsuccessful tension-free vaginal tape operation by shortening pre-implanted tape. J Urol. Jun. 2006;175(6):2196-9. discussion 9–200. Case-series. [pmid: 16697839].
2671 Lobel RW, Davis GD. Long-term results of laparoscopic Burch urethropexy. J Am Assoc Gynecol Laparosc. May. 1997;4(3):341-5. Case-series. [pmid: 9154783].
2672 Lobel RW, Sand PK. Incisional hernia after suprapubic catheterization. Obstet Gynecol. May. 1997;89(5 Pt 2):844-6. Case Reports. [pmid: 9166345].
2673 Locher JL, Burgio KL, Goode PS, et al. Effects of age and causal attribution to aging on health-related behaviors associated with urinary incontinence in older women. Gerontologist. Aug. 2002;42(4):515-21. Not eligible outcomes. [pmid: 12145379].
2674 Locher JL, Goode PS, Roth DL, et al. Reliability assessment of the bladder diary for urinary incontinence in older women. J Gerontol A Biol Sci Med Sci. Jan. 2001;56(1):M32-5. Not eligible outcomes. [pmid: 11193230].
2675 Lock G, Zeuner M, Lang B, et al. Anorectal function in systemic sclerosis: correlation with esophageal dysfunction?. Dis Colon Rectum. Nov. 1997;40(11):1328-35. Case-series. [pmid: 9369108].
2676 Lockhart JL, Ellis GF, Helal M, et al. Combined cystourethropexy for the treatment of type 3 and complicated female urinary incontinence. J Urol. Apr. 1990;143(4):722-5. Case-series. [pmid: 2107335].
2677 Lockhart JL, Pow-Sang JM, Persky L, et al. A continent colonic urinary reservoir: the Florida pouch. J Urol. Oct. 1990;144(4):864-7. Case-series. [pmid: 2398560].
2678 Lockhart JL, Pow-Sang JM, Persky L, et al. Results, complications and surgical indications of the Florida pouch. Surg Gynecol Obstet. Oct. 1991;173(4):289-96. Case-series. [pmid: 1925899].
2679 Loening-Baucke V. Efficacy of biofeedback training in improving faecal incontinence and anorectal physiologic function. Gut. Dec. 1990;31(12):1395-402. Not eligible target population. [pmid: 2265781]. [pmcid: 1378764].
2680 Loharuka S, Barrett J, Roe B. Incontinence and falls in older people: is there a link?. Nurs Times. Nov 22–28. 2005;101(47):52-4. Comment. [pmid: 16329277].
2681 Londono-Schimmer EE, Garcia-Duperly R, Nicholls RJ, et al. Overlapping anal sphincter repair for faecal incontinence due to sphincter trauma: five year follow-up functional results. Int J Colorectal Dis. May. 1994;9(2):110-3. Review. [pmid: 8064190].
2682 Long CY, Hsu SC, Chang Y, et al. The clinical and urodynamic effects of the tension free bladder neck sling procedure. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):344-9. Case-series. [pmid: 15580422].
2683 Long CY, Hsu SC, Wu TP, et al. Urodynamic comparison of continent and incontinent women with severe uterovaginal prolapse. J Reprod Med. Jan. 2004;49(1):33-7. Not eligible outcomes. [pmid: 14976793].
2684 Long CY, Juan YS, Liu CM, et al. Concomitant resection of congenital vaginal septum during the tension-free vaginal tape procedure. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):311-2. Case-reports. [pmid: 16211370].
2685 Long R. Continence by design. Contemp Longterm Care 1999 Aug; 22(8):36–8, 40. Comment
2686 Long R. Ingenuity encounters incontinence. Contemp Longterm Care. Jun. 2001;24(6):24-8. Comment. [pmid: 11417097].
2687 Lopez A, Holmstrom B, Nilsson BY, et al. Paradoxical sphincter reaction is influenced by rectal filling volume. Dis Colon Rectum. Aug. 1998;41(8):1017-22. Case-series. [pmid: 9715159].
2688 Lopez A, Nilsson BY, Mellgren A, et al. Electromyography of the external anal sphincter: comparison between needle and surface electrodes. Dis Colon Rectum. Apr. 1999;42(4):482-5. Not eligible exposure. [pmid: 10215048].
2689 Lottmann HB, Margaryan M, Lortat-Jacob S, et al. Long-term effects of dextranomer endoscopic injections for the treatment of urinary incontinence: an update of a prospective study of 61 patients. J Urol. Oct. 2006;176(4 Pt 2):1762-6. Not eligible target population. [pmid: 16945642].
2690 Lovatsis D, Gupta C, Dean E, et al. Tension-free vaginal tape procedure is an ideal treatment for obese patients. Am J Obstet Gynecol. Dec. 2003;189(6):1601-4. discussion 4–5. Case-series. [pmid: 14710079].
2691 Low G, Shenoy AK, Gilmour AR, et al. A randomized comparison of retention balloon and standard tip rectal catheters in preventing incontinence during double-contrast barium enema. AJR Am J Roentgenol. Sep. 2006;187(3):702-5. Not eligible outcomes. [pmid: 16928933].
2692 Low SJ, Smith KM, Holt EM. Tension free vaginal tape: is the intra-operative cough test necessary?. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):328-30. Case-series. [pmid: 15580418].
2693 Lowe BA. Preservation of the anterior urethral ligamentous attachments in maintaining post-prostatectomy urinary continence: a comparative study. J Urol. Dec. 1997;158(6):2137-41. Case-series. [pmid: 9366330].
2694 Lu WT, Chen CC. Factors affecting postoperative fecal soiling in Hirschsprung's disease. J Formos Med Assoc. Mar. 1998;97(3):170-3. Not eligible target population. [pmid: 9549266].
2695 Luangkhot R, Peng BC, Blaivas JG. Ileocecocystoplasty for the management of refractory neurogenic bladder: surgical technique and urodynamic findings. J Urol. Nov. 1991;146(5):1340-4. Case-series. [pmid: 1942287].
2696 Lubeck DP, Prebil LA, Peeples P, et al. A health related quality of life measure for use in patients with urge urinary incontinence: a validation study. Qual Life Res. Jun. 1999;8(4):337-44. Not eligible outcomes. [pmid: 10472166].
2697 Luber KM, Boero S, Choe JY. The demographics of pelvic floor disorders: current observations and future projections. Am J Obstet Gynecol. Jun. 2001;184(7):1496-501. discussion 501–3. Not eligible level of evidence. [pmid: 11408873].
2698 Luck AM, Galvin SL, Theofrastous JP. Suture erosion and wound dehiscence with permanent versus absorbable suture in reconstructive posterior vaginal surgery. Am J Obstet Gynecol. May. 2005;192(5):1626-9. Not eligible outcomes. [pmid: 15902168].
2699 Luk JK, Cheung RT, Ho SL, et al. Does age predict outcome in stroke rehabilitation? A study of 878 Chinese subjects. Cerebrovasc Dis. 2006;21(4):229-34. Question 1. [pmid: 16446535].
2700 Lukac M, Krstic Z, Sindjic S, et al. Continent appendicostomy in the treatment of fecal incontinence. Acta Chir Iugosl. 2004;51(2):139-40. Not eligible target population. [pmid: 15771306].
2701 Lukacz ES, Lawrence JM, Buckwalter JG, et al. Epidemiology of prolapse and incontinence questionnaire: validation of a new epidemiologic survey. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):272-84. Not eligible outcomes. [pmid: 15856132].
2702 Lukacz ES, Luber KM, Nager CW. The effects of the tension-free vaginal tape on proximal urethral position: a prospective, longitudinal evaluation. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):179-84. discussion 84. Case-series. [pmid: 12955339].
2703 Lukacz ES, Luber KM, Nager CW. The effects of the tension-free vaginal tape on voiding function: a prospective evaluation. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):32-8. discussion 8. Not eligible target population. [pmid: 14752596].
2704 Lumley J, Small R, Brown S, et al. PRISM (Program of Resources, Information and Support for Mothers) Protocol for a community-randomised trial [ISRCTN03464021]. BMC Public Health. Nov 20. 2003;3:36. Not associative hypothesis tested. [pmid: 14629776]. [pmcid: 305350].
2705 Lumley J, Watson L, Small R, et al. PRISM (Program of Resources, Information and Support for Mothers): a community-randomised trial to reduce depression and improve women's physical health six months after birth [ISRCTN03464021]. BMC Public Health. 2006;6:37. Not eligible outcomes. [pmid: 16483383]. [pmcid: 1479326].
2706 Lundqvist C, Siosteen A, Blomstrand C, et al. Spinal cord injuries. Clinical, functional, and emotional status. Spine. Jan. 1991;16(1):78-83. Case-series. [pmid: 2003241].
2707 Lunniss PJ, Kamm MA, Phillips RK. Factors affecting continence after surgery for anal fistula. Br J Surg. Sep. 1994;81(9):1382-5. Case-series. [pmid: 7953425].
2708 Lusky K. Care is the cure. Incontinence calls for individualized treatment. Contemp Longterm Care. Dec. 1994;17(12):49-50. Comment. [pmid: 10138995].
2709 Luther SL, Nelson A, Powell-Cope G. Provider attitudes and beliefs about clinical practice guidelines. SCI Nurs. Winter. 2004;21(4):206-12. Not eligible target population. [pmid: 15794420].
2710 Lyder CH, Clemes-Lowrance C, Davis A, et al. Structured skin care regimen to prevent perineal dermatitis in the elderly. J ET Nurs. Jan–Feb. 1992;19(1):12-6. Not eligible outcomes. [pmid: 1734977].
2711 Lynch AC, Wong C, Anthony A, et al. Bowel dysfunction following spinal cord injury: a description of bowel function in a spinal cord-injured population and comparison with age and gender matched controls. Spinal Cord. Dec. 2000;38(12):717-23. Not eligible target population. [pmid: 11175370].
2712 Lyons DL, Blum T, Curtin PM, et al. Improving care of the older adult. Medsurg Nurs 2006 Jun; 15(3):176–7, 81. Comment
2713 Lyons SS, Specht JK. Prompted voiding protocol for individuals with urinary incontinence. J Gerontol Nurs. Jun. 2000;26(6):5-13. No associative hypothesis tested.
2714 Ma SS. The prevalence of adult female urinary incontinence in Hong Kong Chinese. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(6):327-31. Not eligible level of evidence. [pmid: 9609329].
2715 Maas CP, Moriya Y, Steup WH, et al. Radical and nerve-preserving surgery for rectal cancer in The Netherlands: a prospective study on morbidity and functional outcome. Br J Surg. Jan. 1998;85(1):92-7. Case-series. [pmid: 9462393].
2716 Maas CP, Moriya Y, Steup WH, et al. A prospective study on radical and nerve-preserving surgery for rectal cancer in the Netherlands. Eur J Surg Oncol. Dec. 2000;26(8):751-7. Case-series. [pmid: 11087640].
2717 Maas CP, ter Kuile MM, Laan E, et al. Objective assessment of sexual arousal in women with a history of hysterectomy. Bjog. May. 2004;111(5):456-62. Not eligible outcomes. [pmid: 15104610].
2718 Macaulay AJ, Stern RS, Stanton SL. Psychological aspects of 211 female patients attending a urodynamic unit. J Psychosom Res. 1991;35(1):1-10. Not eligible outcomes.
2719 Macaulay M, Clarke OS, Fader M, et al. Are washable absorbents effective at containing urinary incontinence?. Nurs Times. Mar 23–29. 2004;100(12):58-62. Not eligible exposure.
2720 MacDiarmid S, Rosenberg M. Overactive bladder in women: symptom impact and treatment expectations. Curr Med Res Opin. Sep. 2005;21(9):1413-21. Not eligible level of evidence. [pmid: 16197660].
2721 MacDonagh RP, Forster DM, Thomas DG. Urinary continence in spinal injury patients following complete sacral posterior rhizotomy. Br J Urol. Dec. 1990;66(6):618-22. Case-series. [pmid: 2265335].
2722 MacDonald A, Smith A, McNeill AD, et al. Manual dilatation of the anus. Br J Surg. Dec. 1992;79(12):1381-2. Case-series. [pmid: 1486447].
2723 MacDonald CD, Butler L. Silent no more: elderly women's stories of living with urinary incontinence in long-term care. J Gerontol Nurs. Jan. 2007;33(1):14-20. Case-series.
2724 MacGibbon A, Brieger G, Korda A. Incisionless cystourethropexy—the Intac device—an initial experience. Aust N Z J Obstet Gynaecol. Feb. 2000;40(1):59-61. Case-series. [pmid: 10870781].
2725 Machi J, Oishi AJ, Furumoto NL, et al. Sonographically guided radio frequency thermal ablation for unresectable recurrent tumors in the retroperitoneum and the pelvis. J Ultrasound Med. May. 2003;22(5):507-13. Case-series. [pmid: 12751862].
2726 MacKay K, Hemmett L. Needs assessment of women with urinary incontinence in a district health authority. Br J Gen Pract. Oct. 2001;51(471):801-4. Not eligible level of evidence. [pmid: 11677702]. [pmcid: 1314124].
2727 Mackin B. Evaluating bodyworn continence pads. Nurs Stand. Jan 31–Feb 6. 1990;4(19):36-9. Not eligible target population. [pmid: 2107433].
2728 MacLeod M, Kelly R, Robb SA, et al. Bladder dysfunction in Duchenne muscular dystrophy. Arch Dis Child. Apr. 2003;88(4):347-9. Not eligible target population. [pmid: 12651768]. [pmcid: 1719531].
2729 Madalinska JB, Essink-Bot ML, de Koning HJ, et al. Health-related quality-of-life effects of radical prostatectomy and primary radiotherapy for screen-detected or clinically diagnosed localized prostate cancer. J Clin Oncol. Mar 15. 2001;19(6):1619-28. Case-series. [pmid: 11250990].
2730 Madbouly KM, Senagore AJ, Delaney CP, et al. Clinically based management of rectal prolapse. Surg Endosc. Jan. 2003;17(1):99-103. Case-series. [pmid: 12360372].
2731 Madden MV, Neale KF, Nicholls RJ, et al. Comparison of morbidity and function after colectomy with ileorectal anastomosis or restorative proctocolectomy for familial adenomatous polyposis. Br J Surg. Jul. 1991;78(7):789-92. Case-series. [pmid: 1651799].
2732 Madersbacher H, Halaska M, Voigt R, et al. A placebo-controlled, multicentre study comparing the tolerability and efficacy of propiverine and oxybutynin in patients with urgency and urge incontinence. BJU Int. Oct. 1999;84(6):646-51. Not eligible exposure. [pmid: 10510109].
2733 Madersbacher HG, Iwatsubo E, Perkash I, et al. Clinical Case of the Month: Urology. urinary incontinence in a male paraparetic patient (able to walk) with a mixed lower motor neuron lesion. Spinal Cord. Aug. 1997;35(8):498-502. Case- Reports. [pmid: 9267913].
2734 Madersbacher S, Mohrle K, Burkhard F, et al. Long-term voiding pattern of patients with ileal orthotopic bladder substitutes. J Urol. May. 2002;167(5):2052-7. Case-series. [pmid: 11956437].
2735 Madiba TE, Moodley MM. Anal sphincter reconstruction for incontinence due to non-obstetric sphincter damage. East Afr Med J. Nov. 2003;80(11):585-8. Case-series. [pmid: 15248677].
2736 Madjar S, Beyar M, Nativ O. Transvaginal bone anchored sling. Urology. Mar. 2000;55(3):422-6. Case-series. [pmid: 10699625].
2737 Madjar S, Covington-Nichols C, Secrest CL. New periurethral bulking agent for stress urinary incontinence: modified technique and early results. J Urol. Dec. 2003;170(6 Pt 1):2327-9. Case-series. [pmid: 14634407].
2738 Madjar S, Frischer Z, Nieder AM, et al. Bladder wall abscess following midurethral sling procedure. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2006;17(2):180-1. Case Reports. [pmid: 15965577].
2739 Madjar S, Gousse A. Postirradiation vesicovaginal fistula completely resolved with conservative treatment. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(6):405-6. Case- Reports. [pmid: 11795646].
2740 Madjar S, Jacoby K, Giberti C, et al. Bone anchored sling for the treatment of post-prostatectomy incontinence. J Urol. Jan. 2001;165(1):72-6. Case-series. [pmid: 11125367].
2741 Madjar S, Tchetgen MB, Van Antwerp A, et al. Urethral erosion of tension-free vaginal tape. Urology. Apr. 2002;59(4):601. Case Reports. [pmid: 11927331].
2742 Madoff RD, Rosen HR, Baeten CG, et al. Safety and efficacy of dynamic muscle plasty for anal incontinence: lessons from a prospective, multicenter trial. Gastroenterology. Mar. 1999;116(3):549-56. Not eligible target population. [pmid: 10029613].
2743 Maeda K, Maruta M, Sato H, et al. Effect of oral diazepam on anal continence after low anterior resection: a preliminary study. Tech Coloproctol. Apr. 2002;6(1):15-8. Case-series. [pmid: 12077635].
2744 Magera JS Jr, Elliott DS. Tandem transcorporal artificial urinary sphincter cuff salvage technique: surgical description and results. J Urol. Mar. 2007;177(3):1015-9. discussion 9–20. Case-series. [pmid: 17296400].
2745 Maglinte DD, Kelvin FM, Fitzgerald K, et al. Association of compartment defects in pelvic floor dysfunction. AJR Am J Roentgenol. Feb. 1999;172(2):439-44. Not eligible outcomes. [pmid: 9930799].
2746 Mahadewa T, Harsan H, Nugroho S, et al. Postoperative recovery of complete sudden paraplegia due to lumbar schwannoma. Case report. J Neurosurg Spine. May. 2005;2(5):601-3. Case Reports. [pmid: 15945436].
2747 Mahajan ST, Elkadry EA, Kenton KS, et al. Patient-centered surgical outcomes: the impact of goal achievement and urge incontinence on patient satisfaction one year after surgery. Am J Obstet Gynecol. Mar. 2006;194(3):722-8. Not eligible outcomes. [pmid: 16522404].
2748 Mahendrarajah K, Van der Schaaf AA, Lovegrove FT, et al. Surgery for severe constipation: the use of radioisotope transit scan and barium evacuation proctography in patient selection. Aust N Z J Surg. Mar. 1994;64(3):183-6. Case-series. [pmid: 8117196].
2749 Maher C, Carey M, Dwyer P, et al. Pubovaginal or vicryl mesh rectus fascia sling in intrinsic sphincter deficiency. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):111-6. Case-series. [pmid: 11374508].
2750 Maher CF, Dwyer PL, Carey MP, et al. Colposuspension or sling for low urethral pressure stress incontinence?. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(6):384-9. Case-series. [pmid: 10614975].
2751 Maheswaran CM, MacKinnon AE. Ambulant? Continent? The missing link. Eur J Pediatr Surg. Dec. 2002;12(Suppl 1):S25-6. Case Reports. [pmid: 12585248].
2752 Mahran MR, Ghoneim MA. The application of the modified rectal bladder in management of the compromized urethral damage. Scand J Urol Nephrol. Mar. 1994;28(1):49-53. Case-series. [pmid: 8009193].
2753 Maito JM, Quam ZA, Craig E, et al. Predictors of successful pessary fitting and continued use in a nurse-midwifery pessary clinic. J Midwifery Womens Health. Mar–Apr. 2006;51(2):78-84. Not eligible outcomes. [pmid: 16504903].
2754 Major H, Culligan P, Heit M. Urethral sphincter morphology in women with detrusor instability. Obstet Gynecol. Jan. 2002;99(1):63-8. Not eligible outcomes. [pmid: 11777512].
2755 Majoros A, Bach D, Keszthelyi A, et al. Urinary incontinence and voiding dysfunction after radical retropubic prostatectomy (prospective urodynamic study). Neurourol Urodyn. 2006;25(1):2-7. Case-series. [pmid: 16224797].
2756 Malaga S, Pardo R, Malaga I, et al. Renal involvement in Down syndrome. Pediatr Nephrol. May. 2005;20(5):614-7. Case-series. [pmid: 15785939].
2757 Maliski SL, Heilemann MV, McCorkle R. Mastery of postprostatectomy incontinence and impotence: his work, her work, our work. Oncol Nurs Forum. Jul. 2001;28(6):985-92. Not eligible outcomes. [pmid: 11475885].
2758 Mallipeddi PK, Steele AC, Kohli N, et al. Anatomic and functional outcome of vaginal paravaginal repair in the correction of anterior vaginal wall prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):83-8. Case-series. [pmid: 11374518].
2759 Malm J, Kristensen B, Stegmayr B, et al. Three-year survival and functional outcome of patients with idiopathic adult hydrocephalus syndrome. Neurology. Aug 22. 2000;55(4):576-8. Case-series. [pmid: 10953197].
2760 Malone DC, Okano GJ. Treatment of urge incontinence in Veterans Affairs medical centers. Clin Ther. May. 1999;21(5):867-77. Not eligible outcomes. [pmid: 10397381].
2761 Malone-Lee J, Henshaw DJ, Cummings K. Urodynamic verification of an overactive bladder is not a prerequisite for antimuscarinic treatment response. BJU Int. Sep. 2003;92(4):415-7. Not eligible outcomes. [pmid: 12930431].
2762 Malone-Lee JG, Walsh JB, Maugourd MF. Tolterodine: a safe and effective treatment for older patients with overactive bladder. J Am Geriatr Soc. Jun. 2001;49(6):700-5. Not eligible exposure. [pmid: 11454106].
2763 Maloney C. Evaluation and treatment of urinary incontinence: a primary care approach. Nurse Pract. Feb. 1995;20(2):74-5. Comment. [pmid: 7715870].
2764 Maloney C. Patient with stress urinary incontinence. Answers and discussion of urinary health case study. Lippincotts Prim Care Pract. Nov–Dec. 1997;1(5):567-71. Case- Reports. [pmid: 9384148].
2765 Maloney C. Patient with stress urinary incontinence. Lippincotts Prim Care Pract. Sep–Oct. 1997;1(4):448-9. Case report. [pmid: 9313541].
2766 Maloney C, Cafiero M. Implementing an incontinence program in long-term care settings. A multidisciplinary approach. J Gerontol Nurs. Jun. 1999;25(6):47-52. Case Reports. [pmid: 10603814].
2767 Malouf AJ, Halligan S, Williams AB, et al. Prospective assessment of interobserver agreement for endoanal MRI in fecal incontinence. Abdom Imaging. Jan–Feb. 2001;26(1):76-8. Not eligible outcomes. [pmid: 11116366].
2768 Malouf AJ, Norton CS, Engel AF, et al. Long-term results of overlapping anterior anal-sphincter repair for obstetric trauma. Lancet. Jan 22. 2000;355(9200):260-5. Case-series. [pmid: 10675072].
2769 Malouf AJ, Vaizey CJ, Nicholls RJ, et al. Permanent sacral nerve stimulation for fecal incontinence. Ann Surg. Jul. 2000;232(1):143-8. Case-series. [pmid: 10862207]. [pmcid: 1421119].
2770 Malouf AJ, Vaizey CJ, Norton CS, et al. Internal anal sphincter augmentation for fecal incontinence using injectable silicone biomaterial. Dis Colon Rectum. Apr. 2001;44(4):595-600. Case-series. [pmid: 11330591].
2771 Malouf AJ, Williams AB, Halligan S, et al. Prospective assessment of accuracy of endoanal MR imaging and endosonography in patients with fecal incontinence. AJR Am J Roentgenol. Sep. 2000;175(3):741-5. Not eligible outcomes. [pmid: 10954460].
2772 Maly RC, Hirsch SH, Reuben DB. The performance of simple instruments in detecting geriatric conditions and selecting community-dwelling older people for geriatric assessment. Age Ageing. May. 1997;26(3):223-31. Not eligible outcomes. [pmid: 9223719].
2773 Mander BJ, Abercrombie JF, George BD, et al. The electrically stimulated gracilis neosphincter incorporated as part of total anorectal reconstruction after abdominoperineal excision of the rectum. Ann Surg. Dec. 1996;224(6):702-9. discussion 9–11. [pmid: 8968225]. [pmcid: 1235464].
2774 Mander BJ, Wexner SD, Williams NS, et al. Preliminary results of a multicentre trial of the electrically stimulated gracilis neoanal sphincter. Br J Surg. Dec. 1999;86(12):1543-8. Not eligible target population. [pmid: 10594503].
2775 Manderson L. Boundary breaches: the body, sex and sexuality after stoma surgery. Soc Sci Med. Jul. 2005;61(2):405-15. Not eligible outcomes. [pmid: 15893055].
2776 Mangnall J, Taylor P, Thomas S, et al. Continence problems in care homes: auditing assessment and treatment. Nurs Older People. Mar. 2006;18(2):20-2. Comment.
2777 Manikandan R, Kujawa M, Pearson E, et al. Results of the tension-free vaginal tape procedure for stress incontinence: patient's perspective. Int J Urol. Apr. 2004;11(4):206-12. Case-series. [pmid: 15028098].
2778 Mansi MK. Continent urinary undiversion to modified ureterosigmoidostomy in bladder extrophy patients. World J Surg. Feb. 1999;23(2):207-13. Case-series. [pmid: 9880434].
2779 Mansson A, Anderson H, Colleen S. Time lag to diagnosis of bladder cancer—influence of psychosocial parameters and level of health-care provision. Scand J Urol Nephrol. 1993;27(3):363-9. Not eligible exposure. [pmid: 8290917].
2780 Manunta A, Guille F, Patard JJ, et al. Artificial sphincter insertion after radiotherapy: is it worthwhile?. BJU Int. Mar. 2000;85(4):490-2. Case-series. [pmid: 10691830].
2781 Marano I, Grassi R, Donnianni T, et al. CT and anal endosonography in the evaluation of electrically stimulated neoanal sphincter: a preliminary report. Abdom Imaging. Jul–Aug. 1996;21(4):353-6. Case-series. [pmid: 8661582].
2782 Marcello PW, Barrett RC, Coller JA, et al. Fatigue rate index as a new measurement of external sphincter function. Dis Colon Rectum. Mar. 1998;41(3):336-43. Case Reports. [pmid: 9514429].
2783 Marchal F, Doucet C, Lechaux D, et al. Secondary implantation of an artificial sphincter after abdominoperineal resection and pseudocontinent perineal colostomy for rectal cancer. Gastroenterol Clin Biol. Apr. 2005;29(4):425-8. Case-reports. [pmid: 15864207].
2784 Margossian H, Pollard RR, Walters MD. Small bowel obstruction in a peritoneal defect after laparoscopic Burch procedure. J Am Assoc Gynecol Laparosc. Aug. 1999;6(3):343-5. Case Reports. [pmid: 10459040].
2785 Mariano MB, Tefilli MV, Graziottin TM, et al. Laparoscopic prostatectomy for benign prostatic hyperplasia—a six-year experience. Eur Urol. Jan. 2006;49(1):127-31. discussion 31–2. Case-series. [pmid: 16314034].
2786 Marin R, Francis JM. A case of idiopathic fecal incontinence. Evaluation and management. Am J Phys Med Rehabil. Jul–Aug. 1997;76(4):333-7. Case- Reports. [pmid: 9267194].
2787 Marinkovic S. Adjusting bladder neck sling length to maximise same-day voiding. Bjog. Sep. 2006;113(9):1092-5. Case-series. [pmid: 16956342].
2788 Marinkovic SP, Stanton SL. Triple compartment prolapse: sacrocolpopexy with anterior and posterior mesh extensions. Bjog. Mar. 2003;110(3):323-6. Case-series. [pmid: 12628277].
2789 Marklund-Bau H, Edell-Gustafsson U, Spangberg A. Bothersome urinary symptoms and disease-specific quality of life in patients with benign prostatic obstruction. Scand J Urol Nephrol. 2007;41(1):32-41. Case Reports. [pmid: 17366100].
2790 Marret E, Pruszkowski O, Deleuze A, et al. Accelerated idioventricular rhythm associated with desflurane administration. Anesth Analg. Aug. 2002;95(2):319-21. table of contents. Case Reports. [pmid: 12145043].
2791 Marshall FF, Mostwin JL, Radebaugh LC, et al. Ileocolic neobladder post-cystectomy: continence and potency. J Urol. Mar. 1991;145(3):502-4. Case-series. [pmid: 1997699].
2792 Marshall K, Walsh DM, Baxter GD. The effect of a first vaginal delivery on the integrity of the pelvic floor musculature. Clin Rehabil. Nov. 2002;16(7):795-9. Case-series. [pmid: 12428829].
2793 Marszalek M, Roehlich M, Racz U, et al. Sexual function after tension-free vaginal tape procedure. Urol Int. 2007;78(2):126-9. Not eligible outcomes. [pmid: 17293651].
2794 Martan A, Masata J, Halaska M, et al. Ultrasound imaging of the lower urinary system in women after Burch colposuspension. Ultrasound Obstet Gynecol. Jan. 2001;17(1):58-64. Not eligible outcomes. [pmid: 11244658].
2795 Martignoni E, Nappi RE, Citterio A, et al. Reproductive life milestones in women with Parkinson's disease. Funct Neurol. Oct–Dec. 2003;18(4):211-7. Not eligible level of evidence. [pmid: 15055746].
2796 Martin S. The pharmacists' role in recognizing and treating urinary incontinence. Am Pharm. Jul. 1990;NS30(7):42-5. Comment.
2797 Martinez AM, Ramos NM, Requena JF, et al. Analysis of retropubic colpourethrosuspension results by suburethral sling with REMEEX prosthesis. Eur J Obstet Gynecol Reprod Biol. Feb 10. 2003;106(2):179-83. Case-series. [pmid: 12551789].
2798 Martinez Hernandez Magro P, Villanueva Saenz E, Jaime Zavala M, et al. Endoanal sonography in assessment of fecal incontinence following obstetric trauma. Ultrasound Obstet Gynecol. Dec. 2003;22(6):616-21. Case-series. [pmid: 14689535].
2799 Martinez R. Erdheim-Chester disease: MR of intraaxial and extraaxial brain stem lesions. AJNR Am J Neuroradiol. Oct. 1995;16(9):1787-90. Case Reports. [pmid: 8693976].
2800 Martinez-Puente Mdel C, Pascual-Montero JA, Garcia-Olmo D. Customized biofeedback therapy improves results in fecal incontinence. Int J Colorectal Dis. May. 2004;19(3):210-4. Case-series. [pmid: 14530992].
2801 Martins FE, Bennett CJ, Dunn M, et al. Adverse prognostic features of collagen injection therapy for urinary incontinence following radical retropubic prostatectomy. J Urol. Nov. 1997;158(5):1745-9. Not eligible target population. [pmid: 9334592].
2802 Martins FE, Boyd SD. Artificial urinary sphincter in patients following major pelvic surgery and/or radiotherapy: are they less favorable candidates?. J Urol. Apr. 1995;153(4):1188-93. Case-series. [pmid: 7869495].
2803 Martins JL, Pinus J. Use of biofeedback (BFB) in the treatment of fecal incontinence after surgical correction of anorectal malformations by posterior sagittal anorectoplasty (PSARP). Sao Paulo Med J. May–Jun. 1997;115(3):1427-32. Case-series. [pmid: 9532844].
2804 Martis G, D'Elia G, Diana M, et al. Prostatic capsule- and nerve-sparing cystectomy in organ-confined bladder cancer: preliminary results. World J Surg. Oct. 2005;29(10):1277-81. Case-series. [pmid: 16132401].
2805 Mason L, Glenn S, Walton I, et al. The experience of stress incontinence after childbirth. Birth. Sep. 1999;26(3):164-71. Case-series. [pmid: 10655816].
2806 Mason L, Glenn S, Walton I, et al. Women's reluctance to seek help for stress incontinence during pregnancy and following childbirth. Midwifery. Sep. 2001;17(3):212-21. Not eligible outcomes. [pmid: 11502141].
2807 Mason L, Glenn S, Walton I, et al. The instruction in pelvic floor exercises provided to women during pregnancy or following delivery. Midwifery. Mar. 2001;17(1):55-64. Not eligible outcomes. [pmid: 11207105].
2808 Mason M, Tully S. Urinary incontinence in the older acute care population: effects of knowledge, attitudes and beliefs of nurses on continence management. Perspectives. Fall. 2002;26(3):4-9. Comment.
2809 Mason RC, Roach M. Modified pubovaginal sling for treatment of intrinsic sphincteric deficiency. J Urol. Dec. 1996;156(6):1991-4. Not eligible target population. [pmid: 8965334].
2810 Masood S, Djaladat H, Kouriefs C, et al. The 12-year outcome analysis of an endourethral wallstent for treating benign prostatic hyperplasia. BJU Int. Dec. 2004;94(9):1271-4. Case-series. [pmid: 15610103].
2811 Massolt ET, Wooning MM, Stijnen T, et al. Prevalence, impact on the quality of life and pathophysiological determinants of nocturia in urinary incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):132-7. Not eligible outcomes. [pmid: 15789146].
2812 Masson DB, Govier FE. Modified Pereyra bladder neck suspension in patients with intrinsic sphincter deficiency and bladder neck hypermobility: patient satisfaction with a mean follow-up of 4 years. Urology. Feb. 2000;55(2):217-21. discussion 21–2. Case-series. [pmid: 10688082].
2813 Matanyi S, Acs N, Fontanyi Z, et al. Urodynamic investigation of women operated on for genuine stress incontinence. Gynecol Obstet Invest. 1999;48(4):263-6. Case-series. [pmid: 10592430].
2814 Matharu GS, Assassa RP, Williams KS, et al. Objective assessment of urinary incontinence in women: comparison of the one-hour and 24-hour pad tests. Eur Urol. Feb. 2004;45(2):208-12. Not eligible outcomes. [pmid: 14734008].
2815 Matharu GS, Assassa RP, Williams KS, et al. Continence nurse treatment of women's urinary symptoms. Br J Nurs. Feb 12–25. 2004;13(3):140-3. Not eligible level of evidence. [pmid: 14997075].
2816 Mathers SE, Ingram DA, Swash M. Electrophysiology of motor pathways for sphincter control in multiple sclerosis. J Neurol Neurosurg Psychiatry. Nov. 1990;53(11):955-60. Not eligible outcomes. [pmid: 2178181]. [pmcid: 488276].
2817 Matsubara A, Yasumoto H, Mutaguchi K, et al. Impact of radical perineal prostatectomy on urinary continence and quality of life: a longitudinal study of Japanese patients. Int J Urol. Nov. 2005;12(11):953-8. Case-series. [pmid: 16351650].
2818 Matsui M, Enoki M, Matsui Y, et al. Seronegative myasthenia gravis associated with atonic urinary bladder and accommodative insufficiency. J Neurol Sci. Nov. 1995;133(12):197-9. Case- Reports. [pmid: 8583227].
2819 Matsumoto K, Imaoka T, Tomita S, et al. Pineocytoma with massive intratumoral hemorrhage after ventriculoperitoneal shunt—case report. Neurol Med Chir (Tokyo). Dec. 1997;37(12):911-5. Case Reports. [pmid: 9465590].
2820 Matsuo K, Koyama M, Yoshida S, et al. Tension-free vaginal tape procedure with manual-tapping method: a potentially useful technique. J Obstet Gynaecol Res. Jun. 2005;31(3):247-51. Case-series. [pmid: 15916662].
2821 Matsuo K, Takemura M, Koyama M, et al. Bladder tumor found by tension-free vaginal tape procedure. Obstet Gynecol. May. 2003;101(5 Pt 1):937-40. Case Reports. [pmid: 12738154].
2822 Matsuoka H, Desai MB, Wexner SD, et al. A pilot assessment of whether external coil MRI is useful to assess evacuatory disorders. Int J Colorectal Dis. Apr. 2000;15(2):91-5. Case-series. [pmid: 10855550].
2823 Matsuoka H, Mavrantonis C, Wexner SD, et al. Postanal repair for fecal incontinence—is it worthwhile?. Dis Colon Rectum. Nov. 2000;43(11):1561-7. Case-series. [pmid: 11089593].
2824 Matsuoka N, Moriya Y, Akasu T, et al. Long-term outcome of urinary function after extended lymphadenectomy in patients with distal rectal cancer. Eur J Surg Oncol. Mar. 2001;27(2):165-9. Case-series. [pmid: 11289753].
2825 Matsushita K, Yamada K, Sameshima T, et al. Prediction of incontinence following low anterior resection for rectal carcinoma. Dis Colon Rectum. May. 1997;40(5):575-9. Case-series. [pmid: 9152187].
2826 Matsuyama H, Hirata H, Tomimatsu T, et al. Follow up of surgical repair of female pelvic floor disorders by a mailed questionnaire. Int J Urol. Apr. 2006;13(4):389-94. Case-series. [pmid: 16734856].
2827 Mattox TF, Bhatia NN. The prevalence of urinary incontinence or prolapse among white and Hispanic women. Am J Obstet Gynecol. Feb. 1996;174(2):646-8. Not eligible target population. [pmid: 8623800].
2828 Matuszczak E, Lenkiewicz T. Results of surgical treatment of myelomeningocele. Eur J Pediatr Surg. Oct. 2006;16(5):337-42. Not eligible target population. [pmid: 17160779].
2829 Matza LS, Thompson CL, Krasnow J, et al. Test-retest reliability of four questionnaires for patients with overactive bladder: the overactive bladder questionnaire (OAB-q), patient perception of bladder condition (PPBC), urgency questionnaire (UQ), and the primary OAB symptom questionnaire (POSQ). Neurourol Urodyn. 2005;24(3):215-25. Not eligible outcomes. [pmid: 15747340].
2830 Matzel KE, Bittorf B, Gunther K, et al. Rectal resection with low anastomosis: functional outcome. Colorectal Dis. Sep. 2003;5(5):458-64. Not eligible level of evidence. [pmid: 12925081].
2831 Matzel KE, Kamm MA, Stosser M, et al. Sacral spinal nerve stimulation for faecal incontinence: multicentre study. Lancet. Apr 17. 2004;363(9417):1270-6. Not eligible target population. [pmid: 15094271].
2832 Matzel KE, Madoff RD, LaFontaine LJ, et al. Complications of dynamic graciloplasty: incidence, management, and impact on outcome. Dis Colon Rectum. Oct. 2001;44(10):1427-35. Not eligible outcomes. [pmid: 11598470].
2833 Matzel KE, Stadelmaier U, Bittorf B, et al. Bilateral sacral spinal nerve stimulation for fecal incontinence after low anterior rectum resection. Int J Colorectal Dis. Nov. 2002;17(6):430-4. Case- Reports. [pmid: 12355221].
2834 Matzel KE, Stadelmaier U, Hohenfellner M, et al. Electrical stimulation of sacral spinal nerves for treatment of faecal incontinence. Lancet. Oct 28. 1995;346(8983):1124-7. Case- Reports. [pmid: 7475602].
2835 Matzel KE, Stadelmaier U, Hohenfellner M, et al. Chronic sacral spinal nerve stimulation for fecal incontinence: long-term results with foramen and cuff electrodes. Dis Colon Rectum. Jan. 2001;44(1):59-66. Case-series. [pmid: 11805564].
2836 Matzel KE, Stadelmaier U, Muehldorfer S, et al. Continence after colorectal reconstruction following resection: impact of level of anastomosis. Int J Colorectal Dis. 1997;12(2):82-7. Case-series. [pmid: 9189776].
2837 Maubon AJ, Boncoeur-Martel MP, Juhan V, et al. Static and dynamic MRI of a urinary control intra-vaginal device. Eur Radiol. 2000;10(6):879-84. Case-series. [pmid: 10879694].
2838 Mauk KL. Conservative therapy for urinary incontinence can help older adults. Nursing. Aug. 2005;35(8):20-1. Comment. [pmid: 16062116].
2839 Mavrantonis C, Billotti VL, Wexner SD. Stimulated graciloplasty for treatment of intractable fecal incontinence: critical influence of the method of stimulation. Dis Colon Rectum. Apr. 1999;42(4):497-504. Case-series. [pmid: 10215051].
2840 May RJ. Fecal incontinence in a 39-year-old man. Gastroenterology. Oct. 1991;101(4):1120-6. Case report. [pmid: 1889705].
2841 Mayne CJ, Assassa RP. Epidemiology of incontinence and prolapse. Bjog. Dec. 2004;111(Suppl 1):2-4. No associative hypothesis tested. [pmid: 15663148].
2842 Mayo ME. Lower urinary tract dysfunction in cerebral palsy. J Urol. Feb. 1992;147(2):419-20. Case-series. [pmid: 1732607].
2843 Mazouni C, Karsenty G, Bretelle F, et al. Urinary complications and sexual function after the tension-free vaginal tape procedure. Acta Obstet Gynecol Scand. Oct. 2004;83(10):955-61. Case-series. [pmid: 15453893].
2844 Mazur D, Wehnert J, Dorschner W, et al. Clinical and urodynamic effects of propiverine in patients suffering from urgency and urge incontinence. A multicentre dose-optimizing study. Scand J Urol Nephrol. Sep. 1995;29(3):289-94. Not eligible exposure. [pmid: 8578271].
2845 Mazur DJ, Merz JF. Older patients' willingness to trade off urologic adverse outcomes for a better chance at five-year survival in the clinical setting of prostate cancer. J Am Geriatr Soc. Sep. 1995;43(9):979-84. Not eligible outcomes. [pmid: 7657938].
2846 McCallum TJ, Moore KN, Griffiths D. Urinary incontinence after radical prostatectomy: implications and urodynamics. Urol Nurs 2001 Apr; 21(2):113–9, 24. Not eligible outcomes
2847 McCammon KA, Kolm P, Main B, et al. Comparative quality-of-life analysis after radical prostatectomy or external beam radiation for localized prostate cancer. Urology. Sep. 1999;54(3):509-16. Case series. [pmid: 10475363].
2848 McCarthy M, Addington-Hall J, Altmann D. The experience of dying with dementia: a retrospective study. Int J Geriatr Psychiatry. Mar. 1997;12(3):404-9. Not eligible target population. [pmid: 9152728].
2849 McCarthy M, Lay M, Addington-Hall J. Dying from heart disease. J R Coll Physicians Lond. Jul–Aug. 1996;30(4):325-8. Not eligible target population. [pmid: 8875378].
2850 McCarthy MJ, Aylott CE, Grevitt MP, et al. Cauda equina syndrome: factors affecting long-term functional and sphincteric outcome. Spine. Jan 15. 2007;32(2):207-16. Case-series. [pmid: 17224816].
2851 McClees N, Mikolaj EL, Carlson SL, et al. A pilot study assessing the effectiveness of a glycerin suppository in controlled colostomy emptying. J Wound Ostomy Continence Nurs. May–Jun. 2004;31(3):123-9. Not eligible outcomes. [pmid: 15867741].
2852 McClish DK, Fantl JA, Wyman JF, et al. Bladder training in older women with urinary incontinence: relationship between outcome and changes in urodynamic observations. Obstet Gynecol. Feb. 1991;77(2):281-6. Not eligible target population. [pmid: 1988894].
2853 McClish DK, Wyman JF, Sale PG, et al. Use and costs of incontinence pads in female study volunteers. Continence Program for Women Research Group. J Wound Ostomy Continence Nurs 1999 Jul; 26(4):207–8, 10–3. Not eligible outcomes
2854 McCormick KA. Research. From clinical trial to health policy—research on urinary incontinence in the adult, Part I. J Prof Nurs. May–Jun. 1991;7(3):147. Comment. [pmid: 1905734].
2855 McCormick KA, Cella M, Scheve A, et al. Cost-effectiveness of treating incontinence in severely mobility-impaired long term care residents. QRB Qual Rev Bull. Dec. 1990;16(12):439-43. Not eligible outcomes. [pmid: 2129289].
2856 McCue JL, Thomson JP. Rectopexy for internal rectal intussusception. Br J Surg. Jun. 1990;77(6):632-4. Case-series. [pmid: 2383728].
2857 McCue JL, Thomson JP. Clinical and functional results of abdominal rectopexy for complete rectal prolapse. Br J Surg. Aug. 1991;78(8):921-3. Case-series. [pmid: 1913105].
2858 McDowell BJ. Care of urinary incontinence in the home. Nurse Pract Forum. Sep. 1994;5(3):138-45. Secondary data analysis. [pmid: 7950492].
2859 McDowell BJ, Burgio KL, Candib D. Behavioral and pharmacological treatment of persistent urinary incontinence in the elderly. J Am Acad Nurse Pract. Jan–Mar. 1990;2(1):17-23. Comment. [pmid: 2328159].
2860 McDowell BJ, Burgio KL, Dombrowski M, et al. An interdisciplinary approach to the assessment and behavioral treatment of urinary incontinence in geriatric outpatients. J Am Geriatr Soc. Apr. 1992;40(4):370-4. Case-series. [pmid: 1556364].
2861 McDowell BJ, Engberg S, Weber E, et al. Successful treatment using behavioral interventions of urinary incontinence in homebound older adults. Geriatr Nurs. Nov–Dec. 1994;15(6):303-7. Case- Reports. [pmid: 7835759].
2862 McDowell BJ, Engberg SJ, Rodriguez E, et al. Characteristics of urinary incontinence in homebound older adults. J Am Geriatr Soc. Aug. 1996;44(8):963-8. Case-series. [pmid: 8708309].
2863 McElveen TL, Waterman FM, Kim H, et al. Factors predicting for urinary incontinence after prostate brachytherapy. Int J Radiat Oncol Biol Phys. Aug 1. 2004;59(5):1395-404. Case-series. [pmid: 15275725].
2864 McFall. Pelvic floor electrical stimulation in the treatment of adult urinary incontinence. Tecnologica MAP Suppl 2000 Apr:15–7. Not eligible target population
2865 McFall S, Yerkes AM, Bernard M, et al. Evaluation and treatment of urinary incontinence. Report of a physician survey. Arch Fam Med. Mar–Apr. 1997;6(2):114-9. Not eligible outcomes. [pmid: 9075444].
2866 McFarlane HJ. Anaesthesia and the new generation monoamine oxidase inhibitors. Anaesthesia. Jul. 1994;49(7):597-9. Case- Reports. [pmid: 8042725].
2867 McGhee M, O'Neill K, Major K, et al. Evaluation of a nurse-led continence service in the south-west of Glasgow, Scotland. J Adv Nurs. Oct. 1997;26(4):723-8. Not eligible exposure. [pmid: 9354984].
2868 McGrother CW, Jagger C, Clarke M, et al. Handicaps associated with incontinence: implications for management. J Epidemiol Community Health. Sep. 1990;44(3):246-8. Not eligible level of evidence. [pmid: 2148771]. [pmcid: 1060651].
2869 McGuigan C, Stevens J, Gabriel CM. A synovial cyst in the cervical spine causing acute spinal cord compression. Neurology. Oct 25. 2005;65(8):1293. Case- Reports. [pmid: 16247060].
2870 McGuire EJ, Fitzpatrick CC, Wan J, et al. Clinical assessment of urethral sphincter function. J Urol. Nov. 1993;150(5 Pt 1):1452-4. Not eligible outcomes. [pmid: 8411422].
2871 McIntosh LJ, Frahm JD, Mallett VT, et al. Pelvic floor rehabilitation in the treatment of incontinence. J Reprod Med. Sep. 1993;38(9):662-6. Case-series. [pmid: 8254585].
2872 McIntosh LJ, Mallett VT, Frahm JD, et al. Gynecologic disorders in women with Ehlers-Danlos syndrome. J Soc Gynecol Investig. May–Jun. 1995;2(3):559-64. Case-series.
2873 McIntosh LJ, Richardson DA. 30-minute evaluation of incontinence in the older woman. Geriatrics 1994 Feb; 49(2):35–8, 43–4. Question 4
2874 McIntosh LJ, Stanitski DF, Mallett VT, et al. Ehlers-Danlos syndrome: relationship between joint hypermobility, urinary incontinence, and pelvic floor prolapse. Gynecol Obstet Invest. 1996;41(2):135-9. Case-series. [pmid: 8838976].
2875 McIntyre PB, Pemberton JH, Beart RW Jr, et al. Double-stapled vs. handsewn ileal pouch-anal anastomosis in patients with chronic ulcerative colitis. Dis Colon Rectum. May. 1994;37(5):430-3. Case-series. [pmid: 8181402].
2876 McIntyre PB, Pemberton JH, Wolff BG, et al. Comparing functional results one year and ten years after ileal pouch-anal anastomosis for chronic ulcerative colitis. Dis Colon Rectum. Apr. 1994;37(4):303-7. Case-series. [pmid: 8168407].
2877 McKeever MP. An investigation of recognized incontinence within a health authority. J Adv Nurs. Oct. 1990;15(10):1197-207. Not eligible outcomes. [pmid: 2258528].
2878 McLean C. Continence. The wraps come off. Interview by Jenine Willis. Nurs Times. Oct 9–15. 1996;92(41):72-5. Case Reports. [pmid: 8932160].
2879 McLennan MT. The role of electrodiagnostic techniques in the reprogramming of patients with a delayed suboptimal response to sacral nerve stimulation. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2003;14(2):98-103. Not eligible target population. [pmid: 12851751].
2880 McLennan MT. Transurethral resection of transvaginal tape. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):360-2. Case Reports. [pmid: 15580426].
2881 McLennan MT, Alten B, Melick C, et al. Patients' satisfaction with and attitudes toward vaginal delivery. J Reprod Med. Oct. 2005;50(10):740-4. Not eligible outcomes. [pmid: 16320554].
2882 McLennan MT, Bent AE. Supine empty stress test as a predictor of low valsalva leak point pressure. Neurourol Urodyn. 1998;17(2):121-7. Not eligible outcomes. [pmid: 9514144].
2883 McLennan MT, Melick C, Bent AE. Urethral instability: clinical and urodynamic characteristics. Neurourol Urodyn. 2001;20(6):653-60. Not eligible target population. [pmid: 11746546].
2884 McLennan MT, Melick CF, Alten B, et al. Patients' knowledge of potential pelvic floor changes associated with pregnancy and delivery. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):22-6. Not eligible outcomes. [pmid: 16003482].
2885 McLennan MT, Melick CF, Bent AE. Clinical and urodynamic predictors of delayed voiding after fascia lata suburethral sling. Obstet Gynecol. Oct. 1998;92(4 Pt 1):608-12. Case-series. [pmid: 9764637].
2886 McLennan MT, Melick CF, Bent AE. Leak-point pressure: clinical application of values at two different volumes. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2000;11(3):136-41. Not eligible level of evidence. [pmid: 11484740].
2887 McLennan MT, Melick CF, Cannon S. The position of the urethrovesical junction after incontinence surgery: early postoperative changes. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):44-8. discussion 8. Case-series. [pmid: 14752598].
2888 McMullen D. Candida albicans and incontinence. Dermatol Nurs. Feb. 1991;3(1):21-4. Not eligible exposure. [pmid: 1825278].
2889 McMurdo ME, Davey PG, Elder MA, et al. A cost-effectiveness study of the management of intractable urinary incontinence by urinary catheterisation or incontinence pads. J Epidemiol Community Health. Jun. 1992;46(3):222-6. Not eligible outcomes. [pmid: 1645076]. [pmcid: 1059555].
2890 McPherson K, Herbert A, Judge A, et al. Self-reported bladder function five years post-hysterectomy. J Obstet Gynaecol. Jul. 2005;25(5):469-75. Not eligible level of evidence. [pmid: 16183583].
2891 McVean RJ, Orr A, Webb AK, et al. Treatment of urinary incontinence in cystic fibrosis. J Cyst Fibros. Dec. 2003;2(4):171-6. Case-series. [pmid: 15463869].
2892 McVeigh C. Perimenopause: more than hot flushes and night sweats for some Australian women. J Obstet Gynecol Neonatal Nurs. Jan–Feb. 2005;34(1):21-7. Not eligible level of evidence.
2893 Meade-D'Alisera P, Merriweather T, Wentland M. Impact of commercial marketing on patient demand. Urol Nurs 2001 Dec; 21(6):406–7, 10. Not eligible exposure
2894 Meade-D'Alisera P, Merriweather T, Wentland M, et al. Depressive symptoms in women with urinary incontinence: a prospective study. Urol Nurs. Dec. 2001;21(6):397-9. Not eligible outcomes. [pmid: 11998505].
2895 Meagher AP, Lubowski DZ, King DW. The cough response of the anal sphincter. Int J Colorectal Dis. Dec. 1993;8(4):217-9. Not eligible outcomes. [pmid: 8163897].
2896 Meaglia JP, Joseph AC, Chang M, et al. Post-prostatectomy urinary incontinence: response to behavioral training. J Urol. Sep. 1990;144(3):674-6. Case-series. [pmid: 2388325].
2897 Medina CA, Takacs P. Shortening the process of determining postvoid residual. Int J Gynaecol Obstet. Dec. 2005;91(3):266-7. Not eligible exposure. [pmid: 16226756].
2898 Meehan JJ, Hardin WD Jr, Georgeson KE. Gluteus maximus augmentation for the treatment of fecal incontinence. J Pediatr Surg. Jul. 1997;32(7):1045-7. discussion 7–8. Not eligible target population. [pmid: 9247231].
2899 Mehta KM, Simonsick EM, Penninx BW, et al. Prevalence and correlates of anxiety symptoms in well-functioning older adults: findings from the health aging and body composition study. J Am Geriatr Soc. Apr. 2003;51(4):499-504. Not eligible outcomes. [pmid: 12657069].
2900 Meier U, Zeilinger FS, Kintzel D. Signs, symptoms and course of normal pressure hydrocephalus in comparison with cerebral atrophy. Acta Neurochir (Wien). 1999;141(10):1039-48. Not eligible outcomes. [pmid: 10550647].
2901 Meijer R, van Limbeek J, Peusens G, et al. The Stroke Unit Discharge Guideline, a prognostic framework for the discharge outcome from the hospital stroke unit. A prospective cohort study. Clin Rehabil. Oct. 2005;19(7):770-8. Not eligible outcomes. [pmid: 16250197].
2902 Meinhardt W, Horenblas S. Sexuality preserving cystectomy and neobladder (SPCN): functional results of a neobladder anastomosed to the prostate. Eur Urol. Jun. 2003;43(6):646-50. Not eligible outcomes. [pmid: 12767366].
2903 Melchior H, Kumar V, Muller N, et al. National public health policies for prevention and care in urinary incontinence in the elderly. World J Urol. 1998;16(Suppl 1):S71-3. Not eligible outcomes. [pmid: 9775418].
2904 Mellgren A, Jensen LL, Zetterstrom JP, et al. Long-term cost of fecal incontinence secondary to obstetric injuries. Dis Colon Rectum. Jul. 1999;42(7):857-65. discussion 65–7. Case-series. [pmid: 10411431].
2905 Mellier G, Benayed B, Bretones S, et al. Suburethral tape via the obturator route: is the TOT a simplification of the TVT?. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):227-32. Case-series. [pmid: 15517665].
2906 Meltomaa S, Backman T, Haarala M. Concomitant vaginal surgery did not affect outcome of the tension-free vaginal tape operation during a prospective 3-year followup study. J Urol. Jul. 2004;172(1):222-6. Case-series. [pmid: 15201779].
2907 Meltomaa S, Haarala M, Makinen J, et al. Endoscopic colposuspension with simplified extraperitoneal approach. Tech Urol. Winter. 1997;3(4):216-21. Case-series. [pmid: 9531106].
2908 Meltomaa SS, Haarala MA, Taalikka MO, et al. Outcome of Burch retropubic urethropexy and the effect of concomitant abdominal hysterectomy: a prospective long-term follow-up study. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(1):3-8. Case-series. [pmid: 11294528].
2909 Melton L. Targeted treatment for incontinence beckons. Lancet. Jan 26. 2002;359(9303):326. News. [pmid: 11830208].
2910 Melville JL, Delaney K, Newton K, et al. Incontinence severity and major depression in incontinent women. Obstet Gynecol. Sep. 2005;106(3):585-92. Not eligible outcomes. [pmid: 16135592].
2911 Melville JL, Newton K, Fan MY, et al. Health care discussions and treatment for urinary incontinence in U.S. women. Am J Obstet Gynecol. Mar. 2006;194(3):729-37. Not eligible outcomes. [pmid: 16522405].
2912 Menard C, Trudel C, Cloutier R. Anal reeducation for postoperative fecal incontinence in congenital diseases of the rectum and anus. J Pediatr Surg. Jun. 1997;32(6):867-9. Not eligible target population. [pmid: 9200088].
2913 Menarini M, Del Popolo G, Di Benedetto P, et al. Trospium chloride in patients with neurogenic detrusor overactivity: is dose titration of benefit to the patients?. Int J Clin Pharmacol Ther. Dec. 2006;44(12):623-32. Not eligible target population. [pmid: 17190372].
2914 Menefee SA, Chesson R, Wall LL. Stress urinary incontinence due to prescription medications: alpha-blockers and angiotensin converting enzyme inhibitors. Obstet Gynecol. May. 1998;91(5 Pt 2):853-4. Case Reports. [pmid: 9572189].
2915 Mentes BB, Tezcaner T, Yilmaz U, et al. Results of lateral internal sphincterotomy for chronic anal fissure with particular reference to quality of life. Dis Colon Rectum. Jul. 2006;49(7):1045-51. Not eligible outcomes. [pmid: 16598404].
2916 Mercer LJ, Ludtke LJ. Adenoma malignum presenting as urinary incontinence. Int J Gynaecol Obstet. Oct. 1991;36(2):149-53. Case report. [pmid: 1683318].
2917 Merrick GS, Butler WM, Lief JH, et al. Temporal resolution of urinary morbidity following prostate brachytherapy. Int J Radiat Oncol Biol Phys. Apr 1. 2000;47(1):121-8. Not eligible outcomes. [pmid: 10758313].
2918 Merrick GS, Butler WM, Wallner K, et al. Permanent prostate brachytherapy-induced morbidity in patients with grade II and III obesity. Urology. Jul. 2002;60(1):104-8. Case-series. [pmid: 12100933].
2919 Merrick GS, Butler WM, Wallner KE, et al. Long-term urinary quality of life after permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. Jun 1. 2003;56(2):454-61. Case series. [pmid: 12738320].
2920 Mertz HR, Beck CK, Dixon W, et al. Validation of a new measure of diarrhea. Dig Dis Sci. Sep. 1995;40(9):1873-82. Not eligible outcomes. [pmid: 7555436].
2921 Meschia M, Bruschi F, Amicarelli F, et al. The sacrospinous vaginal vault suspension: Critical analysis of outcomes. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):155-9. Case-series. [pmid: 10430007].
2922 Meschia M, Busacca M, Pifarotti P, et al. Bowel perforation during insertion of tension-free vaginal tape (TVT). Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(4):263-5. discussion 5. Case Reports. [pmid: 12189433].
2923 Meschia M, Pifarotti P, Bernasconi F, et al. Tension-Free vaginal tape: analysis of outcomes and complications in 404 stress incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S24-7. Not eligible target population. [pmid: 11450976].
2924 Meschia M, Pifarotti P, Buonaguidi A, et al. Tension-free vaginal tape (TVT) for treatment of stress urinary incontinence in women with low-pressure urethra. Eur J Obstet Gynecol Reprod Biol. Sep 1. 2005;122(1):118-21. Case-series. [pmid: 16154048].
2925 Meshkinpour H, Movahedi H, Welgan P. Clinical value of anorectal manometry index in neurogenic fecal incontinence. Dis Colon Rectum. Apr. 1997;40(4):457-61. Not eligible outcomes. [pmid: 9106696].
2926 Messick GM, Powe CE. Applying behavioral research to incontinence. Ostomy Wound Manage 1997 Nov–Dec; 43(10):40–6, 8. Case-reports
2927 Metin A, Kayigil, Ahmed SI. The rate of urgency symptoms in women with stress urinary incontinence and nomogram based bladder outlet obstruction. Int Urol Nephrol. 2000;32(2):251-3. Case-series. [pmid: 11229642].
2928 Metin A, Kayigil O, Ahmed SI. Modified insitu vaginal wall sling in stress incontinence. Int Urol Nephrol. 2001;32(4):641-5. Case-series. [pmid: 11989556].
2929 Meulen T, Zambon JV, Janknegt RA. Treatment of anastomotic strictures and urinary incontinence after radical prostatectomy with urolume wallstent and AMS 800 artificial sphincter. J Endourol. Sep. 1999;13(7):517-20. Case Reports. [pmid: 10569527].
2930 Mevorach RA, Bogaert GA, Baskin LS, et al. Lower urinary tract function in ambulatory children with spina bifida. Br J Urol. Apr. 1996;77(4):593-6. Not eligible target population. [pmid: 8777626].
2931 Meyenberger C, Bertschinger P, Zala GF, et al. Anal sphincter defects in fecal incontinence: correlation between endosonography and surgery. Endoscopy. Feb. 1996;28(2):217-24. Case-series. [pmid: 8739736].
2932 Meyer S, Achtari C, Hohlfeld P, et al. Effects of epidural analgesia on pelvic floor function after spontaneous delivery: a longitudinal retrospective study. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2002;13(6):359-64. discussion 64–5. Case-series. [pmid: 12466906].
2933 Meyer S, Bachelard O, De Grandi P. Do bladder neck mobility and urethral sphincter function differ during pregnancy compared with during the non-pregnant state?. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(6):397-404. Question 2. [pmid: 9891962].
2934 Meyer S, de Grandi P, Caccia G, et al. Pressure transmission ratio: is it a reliable parameter in increased urethro-vesical junction mobility?. Neurourol Urodyn. 1997;16(4):277-84. Not eligible outcomes. [pmid: 9220476].
2935 Meyer S, Dhenin T, Schmidt N, et al. Subjective and objective effects of intravaginal electrical myostimulation and biofeedback in patients with genuine stress urinary incontinence. Br J Urol. Jun. 1992;69(6):584-8. Case-series. [pmid: 1638343].
2936 Meyer S, Kuntzer T, Newsom N, et al. Stress urinary incontinence due to a low-pressure urethra: a socially invalidizing disease. Neurourol Urodyn. 1996;15(3):177-86. Not eligible outcomes. [pmid: 8732984].
2937 Meyer S, Schreyer A, De Grandi P, et al. The effects of birth on urinary continence mechanisms and other pelvic-floor characteristics. Obstet Gynecol. Oct. 1998;92(4 Pt 1):613-8. Not eligible level of evidence. [pmid: 9764638].
2938 Michel MC, de la Rosette JJ, Piro M, et al. Does concomitant stress incontinence alter the efficacy of tolterodine in patients with overactive bladder?. J Urol. Aug. 2004;172(2):601-4. Not eligible target population. [pmid: 15247741].
2939 Michel MS, Koehrmann KU, Knoll T, et al. Clinical evaluation of a newly developed endoscopic resection device (Rotoresect): physical principle and first clinical results. Surg Endosc. Dec. 2001;15(12):1395-400. Not eligible exposure. [pmid: 11965453].
2940 Michelassi F, Melis M, Rubin M, et al. Surgical treatment of anorectal complications in Crohn's disease. Surgery. Oct. 2000;128(4):597-603. Not eligible outcomes. [pmid: 11015093].
2941 Michelsen HB, Buntzen S, Krogh K, et al. Rectal volume tolerability and anal pressures in patients with fecal incontinence treated with sacral nerve stimulation. Dis Colon Rectum. Jul. 2006;49(7):1039-44. Case-series. [pmid: 16721520].
2942 Michielsen DP, Wyndaele JJ. Urodynamics and lower urinary tract symptoms. Acta Urol Belg. Oct. 1998;66(3):7-9. Not eligible outcomes. [pmid: 9864870].
2943 Michot F, Costaglioli B, Leroi AM, et al. Artificial anal sphincter in severe fecal incontinence: outcome of prospective experience with 37 patients in one institution. Ann Surg. Jan. 2003;237(1):52-6. Case-series. [pmid: 12496530]. [pmcid: 1513965].
2944 Midthun S, Paur R, Bruce AW. Pyuria detection using a dipstick applied to urine in incontinence pads. Urol Nurs 2003 Dec; 23(6):430–5, 7. Not eligible exposure
2945 Midthun SJ, Paur RA, Lindseth G, et al. Bacteriuria detection with a urine dipstick applied to incontinence pads of nursing home residents. Geriatr Nurs. Jul–Aug. 2003;24(4):206-9. Not eligible exposure. [pmid: 14560290].
2946 Migliari R, De Angelis M, Madeddu G, et al. Tension-free vaginal mesh repair for anterior vaginal wall prolapse. Eur Urol. Aug. 2000;38(2):151-5. Case-series. [pmid: 10895005].
2947 Migliari R, Leone P, Berdondini E, et al. Dorsal buccal mucosa graft urethroplasty for female urethral strictures. J Urol. Oct. 2006;176(4 Pt 1):1473-6. Case-reports. [pmid: 16952664].
2948 Migliari R, Pistolesi D, De Angelis M. Polypropilene sling of the bulbar urethra for post-radical prostatectomy incontinence. Eur Urol. Feb. 2003;43(2):152-7. Case-series. [pmid: 12565773].
2949 Migliari R, Usai E. Treatment results using a mixed fiber mesh in patients with grade IV cystocele. J Urol. Apr. 1999;161(4):1255-8. Case-series. [pmid: 10081880].
2950 Mikami O, Osawa O, Matsuda T, et al. The augmented rectal bladder for urinary diversion: experience with the original valved rectum and a valve-less modification. Int J Urol. Mar. 1994;1(1):57-60. discussion 1. Not eligible exposure. [pmid: 7627839].
2951 Miklos JR, Sze EH, Karram MM. A critical appraisal of the methods of measuring leak-point pressures in women with stress incontinence. Obstet Gynecol. Sep. 1995;86(3):349-52. Not eligible outcomes. [pmid: 7651641].
2952 Milani R, Salvatore S, Soligo M, et al. Functional and anatomical outcome of anterior and posterior vaginal prolapse repair with prolene mesh. Bjog. Jan. 2005;112(1):107-11. Case-series. [pmid: 15663408].
2953 Miles AJ, Allen-Mersh TG, Wastell C. Effect of anoreceptive intercourse on anorectal function. J R Soc Med. Mar. 1993;86(3):144-7. Not eligible level of evidence. [pmid: 8459377]. [pmcid: 1293903].
2954 Miles BJ, Khera M. Can preoperative behavioral training reduce postprostatectomy incontinence?. Nat Clin Pract Urol. Jun. 2006;3(6):302-3. Comment. [pmid: 16763638].
2955 Millard R, Tuttle J, Moore K, et al. Clinical efficacy and safety of tolterodine compared to placebo in detrusor overactivity. J Urol. May. 1999;161(5):1551-5. Not eligible exposure. [pmid: 10210394].
2956 Millard RJ, Halaska M. Efficacy of solifenacin in patients with severe symptoms of overactive bladder: a pooled analysis. Curr Med Res Opin. Jan. 2006;22(1):41-8. Review, meta-analysis. [pmid: 16393429].
2957 Millard RJ, Moore K, Rencken R, et al. Duloxetine vs placebo in the treatment of stress urinary incontinence: a four-continent randomized clinical trial. BJU Int. Feb. 2004;93(3):311-8. Not eligible exposure. [pmid: 14764128].
2958 Millard RJ, Wang Y. Early clinical experience with continent urinary diversion. Aust N Z J Surg. Dec. 1996;66(12):826-9. Case-series. [pmid: 8996064].
2959 Miller AS, Lewis WG, Williamson ME, et al. Factors that influence functional outcome after coloanal anastomosis for carcinoma of the rectum. Br J Surg. Oct. 1995;82(10):1327-30. Case-series. [pmid: 7489154].
2960 Miller AS, Lewis WG, Williamson ME, et al. Does eversion of the anorectum during restorative proctocolectomy influence functional outcome?. Dis Colon Rectum. May. 1996;39(5):489-93. Not eligible outcomes. [pmid: 8620796].
2961 Miller CA. Medications can cause or treat urinary incontinence. Geriatr Nurs. Sep–Oct. 1995;16(5):253-4. Review. [pmid: 7590464].
2962 Miller EJ, Quan SH, Thaler HT. Treatment of squamous cell carcinoma of the anal canal. Cancer. Apr 15. 1991;67(8):2038-41. Case-series. [pmid: 2004321].
2963 Miller GV, Finan PJ. Flap advancement and core fistulectomy for complex rectal fistula. Br J Surg. Jan. 1998;85(1):108-10. Case-series. [pmid: 9462397].
2964 Miller JM, Ashton-Miller JA, Delancey JO. Quantification of cough-related urine loss using the paper towel test. Obstet Gynecol. May. 1998;91(5 Pt 1):705-9. Case-series. [pmid: 9572215].
2965 Miller JS, Ferguson CM, Amerson JR, et al. Ileal pouch-anal anastomosis. The Emory University experience. Am Surg. Feb. 1991;57(2):89-95. Case-series. [pmid: 1847028].
2966 Miller K, Richardson DA, Siegel SW, et al. Pelvic floor electrical stimulation for genuine stress incontinence: who will benefit and when?. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(5):265-70. Not eligible target population. [pmid: 9849758].
2967 Miller K, Wenderoth UK, de Petriconi R, et al. The ileal neobladder. Operative technique and results. Urol Clin North Am. Nov. 1991;18(4):623-30. Comment. [pmid: 1949395].
2968 Miller NL, Bissonette EA, Bahnson R, et al. Impact of a novel neoadjuvant and adjuvant hormone-deprivation approach on quality of life, voiding function, and sexual function after prostate brachytherapy. Cancer. Mar 1. 2003;97(5):1203-10. Not eligible level of evidence. [pmid: 12599226].
2969 Miller R, Bartolo DC, Orrom WJ, et al. Improvement of anal sensation with preservation of the anal transition zone after ileoanal anastomosis for ulcerative colitis. Dis Colon Rectum. May. 1990;33(5):414-8. Case-series. [pmid: 2328630].
2970 Milne J. The impact of information on health behaviors of older adults with urinary incontinence. Clin Nurs Res. May. 2000;9(2):161-76. Not eligible outcomes. [pmid: 12162240].
2971 Milsom I. The prevalence of urinary incontinence. Acta Obstet Gynecol Scand. Dec. 2000;79(12):1056-9. Review. [pmid: 11130087].
2972 Milsom I, Abrams P, Cardozo L, et al. How widespread are the symptoms of an overactive bladder and how are they managed? A population-based prevalence study. BJU Int. Jun. 2001;87(9):760-6. Not eligible target population. [pmid: 11412210].
2973 Mimura T, Kaminishi M, Kamm MA. Diagnostic evaluation of patients with faecal incontinence at a specialist institution. Dig Surg. 2004;21(3):235-41. discussion 41. Not eligible outcomes. [pmid: 15237257].
2974 Minaglia S, Ozel B, Bizhang R, et al. Increased prevalence of interstitial cystitis in women with detrusor overactivity refractory to anticholinergic therapy. Urology. Oct. 2005;66(4):702-6. Not eligible outcomes. [pmid: 16230120].
2975 Minaglia S, Ozel B, Hurtado E, et al. Effect of transobturator tape procedure on proximal urethral mobility. Urology. Jan. 2005;65(1):55-9. Case-series. [pmid: 15667863].
2976 Minaglia S, Ozel B, Klutke C, et al. Bladder injury during transobturator sling. Urology. Aug. 2004;64(2):376-7. Case-series. [pmid: 15302505].
2977 Minassian VA, Al-Badr A, Drutz HP, et al. Tension-free vaginal tape, Burch, and slings: are there predictors for early postoperative voiding dysfunction?. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):183-7. Case-series. [pmid: 15167998].
2978 Minassian VA, Al-Badr A, Pascali DU, et al. Tension-free vaginal tape: do patients who fail to follow-up have the same results as those who do?. Neurourol Urodyn. 2005;24(1):35-8. Case-series. [pmid: 15570579].
2979 Minassian VA, Lovatsis D, Pascali D, et al. Effect of childhood dysfunctional voiding on urinary incontinence in adult women. Obstet Gynecol. Jun. 2006;107(6):1247-51. Not eligible exposure. [pmid: 16738148].
2980 Minervini A, Salinitri G, Minervini R. Retroperitoneal urinoma complicating Burch colposuspension. Int J Gynaecol Obstet. Jul. 2003;82(1):85-6. Not eligible exposure. [pmid: 12834951].
2981 Minervini R, Felipetto R, Morelli G, et al. Urodynamic evaluation of urinary incontinence following radical prostatectomy: our experience. Acta Urol Belg. Dec. 1996;64(4):5-8. Case-series. [pmid: 9008971].
2982 Minervini R, Felipetto R, Morelli G, et al. Bladder instability and incontinence after radical prostatectomy. Biomed Pharmacother. 1996;50(8):383-5. Case-series. [pmid: 8952860].
2983 Mingin GC, Nguyen HT, Mathias RS, et al. Growth and metabolic consequences of bladder augmentation in children with myelomeningocele and bladder exstrophy. Pediatrics. Dec. 2002;110(6):1193-8. Not eligible target population. [pmid: 12456918].
2984 Minguez M, Garrigues V, Soria MJ, et al. Adaptation to Spanish language and validation of the fecal incontinence quality of life scale. Dis Colon Rectum. Apr. 2006;49(4):490-9. Not eligible exposure. [pmid: 16518714].
2985 Minguez M, Melo F, Espi A, et al. Therapeutic effects of different doses of botulinum toxin in chronic anal fissure. Dis Colon Rectum. Aug. 1999;42(8):1016-21. Not eligible outcomes. [pmid: 10458124].
2986 Mishra VC, Mishra N, Karim OM, et al. Voiding dysfunction after tension-free vaginal tape: a conservative approach is often successful. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):210-4. discussion 4. Case-series. [pmid: 15372143].
2987 Mitrani C, Chun A, Desautels S, et al. Anorectal manometric characteristics in men and women with idiopathic fecal incontinence. J Clin Gastroenterol. Apr. 1998;26(3):175-8. Not eligible outcomes. [pmid: 9600364].
2988 Mitropoulos D, Papadoukakis S, Zervas A, et al. Efficacy of tolterodine in preventing urge incontinence immediately after prostatectomy. Int Urol Nephrol. 2006;38(2):263-8. Not eligible exposure. [pmid: 16868694].
2989 Mitterberger M, Pinggera GM, Mueller T, et al. Dynamic transurethral sonography and 3-dimensional reconstruction of the rhabdosphincter and urethra: initial experience in continent and incontinent women. J Ultrasound Med. Mar. 2006;25(3):315-20. Not eligible outcomes. [pmid: 16495491].
2990 Miura T, Tanaka H, Makino Y, et al. Human T cell leukemia virus type I-associated myelopathy in a patient with systemic lupus erythematosus. Intern Med. Jun. 1999;38(6):512-5. Case Reports. [pmid: 10411360].
2991 Mizunaga M, Miyata M, Kaneko S, et al. Intravesical instillation of oxybutynin hydrochloride therapy for patients with a neuropathic bladder. Paraplegia. Jan. 1994;32(1):25-9. Case-series. [pmid: 8015832].
2992 Moalli PA, Jones Ivy S, Meyn LA, et al. Risk factors associated with pelvic floor disorders in women undergoing surgical repair. Obstet Gynecol. May. 2003;101(5 Pt 1):869-74. Not eligible target population. [pmid: 12738142].
2993 Moghimi K, Valbo A. Genital prolapse: a follow-up study assessing subjective and objective results five years or more after surgical intervention. Eur J Obstet Gynecol Reprod Biol. Jun 1. 2005;120(2):198-201. Case-series. [pmid: 15925052].
2994 Mogielnicki RP, Nelson WA, Dulac J. A study of the dying process in elderly hospitalized males. J Cancer Educ. 1990;5(2):135-45. Case-series. [pmid: 2206934].
2995 Mohan KP, Massey JA. Neurofibromatous outflow obstruction. Br J Urol. Sep. 1994;74(3):386-7. Case Reports. [pmid: 7953279].
2996 Molander U. Urinary incontinence and related urogenital symptoms in elderly women. Acta Obstet Gynecol Scand Suppl. 1993;158:1-22. Not eligible level of evidence. [pmid: 8396841].
2997 Molander U, Arvidsson L, Milsom I, et al. A longitudinal cohort study of elderly women with urinary tract infections. Maturitas. Feb 15. 2000;34(2):127-31. Not eligible level of evidence. [pmid: 10714907].
2998 Molander U, Milsom I, Ekelund P, et al. A health care program for the investigation and treatment of elderly women with urinary incontinence and related urogenital symptoms. Acta Obstet Gynecol Scand. 1991;70(2):137-42. Not eligible target population. [pmid: 1882660].
2999 Molander U, Sundh V, Steen B. Urinary incontinence and related symptoms in older men and women studied longitudinally between 70 and 97 years of age. A population study. Archives of Gerontology and Geriatrics. Nov–Dec. 2002;35(3):237-44. Not eligible level of evidence. [pmid: 14764362].
3000 Mollard P, Mouriquand P, Joubert P. Urethral lengthening for neurogenic urinary incontinence (Kropp's procedure): results of 16 cases. J Urol. Jan. 1990;143(1):95-7. Not eligible target population. [pmid: 2294274].
3001 Molmenti EP, Pinto PA, Montgomery RA, et al. Concomitant surgery with laparoscopic live donor nephrectomy. Am J Transplant. Feb. 2003;3(2):219-23. Case-reports. [pmid: 12603216].
3002 Mommsen S, Foldspang A, Elving L, et al. Association between urinary incontinence in women and a previous history of surgery. Br J Urol. Jul. 1993;72(1):30-7. Not eligible level of evidence. [pmid: 8149175].
3003 Monk DN, Mills P, Jeacock J, et al. Combining the strength-duration curve of the external anal sphincter with manometry for the assessment of faecal incontinence. Br J Surg. Oct. 1998;85(10):1389-93. Not eligible outcomes. [pmid: 9782022].
3004 Montague DK. The artificial urinary sphincter (AS 800): experience in 166 consecutive patients. J Urol. Feb. 1992;147(2):380-2. Case-series. [pmid: 1732598].
3005 Montella JM, Ewing S, Cater J. Visual assessment of urethrovesical junction mobility. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(1):13-7. Not eligible outcomes. [pmid: 9260091].
3006 Montorsi F, Guazzoni G, Bergamaschi F, et al. A comparison of transrectal hyperthermia, transurethral thermotherapy, urolume wallstent, and prostatic spiral for benign prostatic hyperplasia patients at poor operative risk. Prostate. 1994;24(3):156-61. Case-series. [pmid: 7509486].
3007 Montorsi F, Salonia A, Suardi N, et al. Improving the preservation of the urethral sphincter and neurovascular bundles during open radical retropubic prostatectomy. Eur Urol. Dec. 2005;48(6):938-45. Case-series. [pmid: 16257111].
3008 Montoya A, Weiss AP, Price BH, et al. Magnetic resonance imaging-guided stereotactic limbic leukotomy for treatment of intractable psychiatric disease. Neurosurgery. May. 2002;50(5):1043-9. discussion 9–52. Case-series. [pmid: 11950407].
3009 Monz B, Pons ME, Hampel C, et al. Patient-reported impact of urinary incontinence—results from treatment seeking women in 14 European countries. Maturitas. Nov 30. 2005;52(Suppl 2):S24-34. Not eligible outcomes. [pmid: 16297579].
3010 Moody G, Probert CS, Srivastava EM, et al. Sexual dysfunction amongst women with Crohn's disease: a hidden problem. Digestion. 1992;52(34):179-83. Not eligible outcomes. [pmid: 1459352].
3011 Moody JA, Lingeman JE. Holmium laser enucleation of the prostate with tissue morcellation: initial United States experience. J Endourol. Mar. 2000;14(2):219-23. Case-series. [pmid: 10772518].
3012 Moore C, Kogan BA, Parekh A. Impact of urinary incontinence on self-concept in children with spina bifida. J Urol. Apr. 2004;171(4):1659-62. Not eligible target population. [pmid: 15017261].
3013 Moore K, Allen M, Voaklander DC. Pad tests and self-reports of continence in men awaiting radical prostatectomy: establishing baseline norms for males. Neurourol Urodyn. 2004;23(7):623-6. No associative hypothesis tested. [pmid: 15382185].
3014 Moore K, Griffiths D, Latimer G, et al. Twenty four-hour monitoring of incontinence and bladder function in a community hospital. J ET Nurs. Jul–Aug. 1993;20(4):163-8. Case-series. [pmid: 8343556].
3015 Moore KH, Foote A, Burton G, et al. An open study of the bladder neck support prosthesis in genuine stress incontinence. Br J Obstet Gynaecol. Jan. 1999;106(1):42-9. Not eligible target population. [pmid: 10426258].
3016 Moore KH, Gilpin SA, Dixon JS, et al. Increase in presumptive sensory nerves of the urinary bladder in idiopathic detrusor instability. Br J Urol. Oct. 1992;70(4):370-2. Not eligible outcomes. [pmid: 1450843].
3017 Moore KH, Goldstein M, Hay D. The treatment of detrusor instability in postmenopausal women with oxybutynin chloride: a double blind placebo controlled study. Br J Obstet Gynaecol. Nov. 1990;97(11):1063-4. Letter. [pmid: 2082973].
3018 Moore KH, Ray FR, Barden JA. Loss of purinergic P2X(3) and P2X(5) receptor innervation in human detrusor from adults with urge incontinence. J Neurosci. Sep 15. 2001;21(18):RC166. Not eligible outcomes. [pmid: 11549755].
3019 Moore KH, Richmond DH, Parys BT. Sex distribution of adult idiopathic detrusor instability in relation to childhood bedwetting. Br J Urol. Nov. 1991;68(5):479-82. Not eligible exposure. [pmid: 1747721].
3020 Moore KH, Simons A, Dowell C, et al. Efficacy and user acceptability of the urethral occlusive device in women with urinary incontinence. J Urol. Aug. 1999;162(2):464-8. Not eligible target population. [pmid: 10411058].
3021 Moore KH, Simons A, Mukerjee C, et al. The relative incidence of detrusor instability and bacterial cystitis detected on the urodynamic-test day. BJU Int. May. 2000;85(7):786-92. Not eligible outcomes. [pmid: 10792153].
3022 Moore KN, Estey A. The early post-operative concerns of men after radical prostatectomy. J Adv Nurs. May. 1999;29(5):1121-9. Case-series. [pmid: 10320495].
3023 Moore RD, Miklos JR, Kohli N. Rectovaginal fistula repair using a porcine dermal graft. Obstet Gynecol. Nov. 2004;104(5 Pt 2):1165-7. Not eligible exposure. [pmid: 15516438].
3024 Moore TF, Saltmarche A. Developing and testing an instrument to assess the information needs of persons with urinary incontinence. Perspectives. Spring. 1993;17(1):2-6. Not eligible outcomes.
3025 Moran F, Bradley JM, Boyle L, et al. Incontinence in adult females with cystic fibrosis: a Northern Ireland survey. Int J Clin Pract. Apr. 2003;57(3):182-3. Case-series. [pmid: 12723720].
3026 Moran PA, Carey MP, Dwyer PL. Urethral diverticula in pregnancy. Aust N Z J Obstet Gynaecol. Feb. 1998;38(1):102-6. Case-reports. [pmid: 9521406].
3027 Moran PA, Ward KL, Johnson D, et al. Tension-free vaginal tape for primary genuine stress incontinence: a two-centre follow-up study. BJU Int. Jul. 2000;86(1):39-42. Case-series. [pmid: 10886080].
3028 Morey AF, Medendorp AR, Noller MW, et al. Transobturator versus transabdominal mid urethral slings: a multi-institutional comparison of obstructive voiding complications. J Urol. Mar. 2006;175(3 Pt 1):1014-7. Case-series. [pmid: 16469607].
3029 Morgan DJ, Blackburn M, Bax M. Adults with spina bifida and/or hydrocephalus. Postgrad Med J. Jan. 1995;71(831):17-21. Case-series. [pmid: 7708585]. [pmcid: 2397906].
3030 Morgan DM, Dunn RL, Fenner DE, et al. Comparative analysis of urinary incontinence severity after autologous fascia pubovaginal sling, pubovaginal sling and tension-free vaginal tape. J Urol. Feb. 2007;177(2):604-8. discussion 8–9. Case-series. [pmid: 17222642].
3031 Morgan JE, Heritz DM, Stewart FE, et al. The polypropylene pubovaginal sling for the treatment of recurrent stress urinary incontinence. J Urol. Sep. 1995;154(3):1013-4. discussion 5–6. Case-series. [pmid: 7637044].
3032 Morgan JL, O'Connell HE, McGuire EJ. Is intrinsic sphincter deficiency a complication of simple hysterectomy?. J Urol. Sep. 2000;164(3 Pt 1):767-9. Not eligible target population. [pmid: 10953143].
3033 Morgan R, Patel B, Beynon J, et al. Surgical management of anorectal incontinence due to internal anal sphincter deficiency. Br J Surg. Feb. 1997;84(2):226-30. Case-series. [pmid: 9052442].
3034 Mori K. Management of idiopathic normal-pressure hydrocephalus: a multiinstitutional study conducted in Japan. J Neurosurg. Dec. 2001;95(6):970-3. Not eligible exposure. [pmid: 11765841].
3035 Morin M, Bourbonnais D, Gravel D, et al. Pelvic floor muscle function in continent and stress urinary incontinent women using dynamometric measurements. Neurourol Urodyn. 2004;23(7):668-74. Not eligible outcomes. [pmid: 15382183].
3036 Morin M, Dumoulin C, Bourbonnais D, et al. Pelvic floor maximal strength using vaginal digital assessment compared to dynamometric measurements. Neurourol Urodyn. 2004;23(4):336-41. Not eligible outcomes. [pmid: 15227651].
3037 Morkved S, Bo K. Prevalence of urinary incontinence during pregnancy and postpartum. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(6):394-8. Not eligible level of evidence. [pmid: 10614977].
3038 Morkved S, Bo K. Effect of postpartum pelvic floor muscle training in prevention and treatment of urinary incontinence: a one-year follow up. Bjog. Aug. 2000;107(8):1022-8. Case-series. [pmid: 10955436].
3039 Morkved S, Salvesen KA, Bo K, et al. Pelvic floor muscle strength and thickness in continent and incontinent nulliparous pregnant women. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2004;15(6):384-9. discussion 90. Question 4. [pmid: 15278255].
3040 Morren GL, Walter S, Hallbook O, et al. Effects of magnetic sacral root stimulation on anorectal pressure and volume. Dis Colon Rectum. Dec. 2001;44(12):1827-33. Case-series. [pmid: 11742169].
3041 Morren GL, Walter S, Lindehammar H, et al. Evaluation of the sacroanal motor pathway by magnetic and electric stimulation in patients with fecal incontinence. Dis Colon Rectum. Feb. 2001;44(2):167-72. Not eligible outcomes. [pmid: 11227931].
3042 Morris AR, Ho MT, Lapsley H, et al. Costs of managing urinary and faecal incontinence in a sub-acute care facility: a “bottom-up” approach. Neurourol Urodyn. 2005;24(1):56-62. Case-series. [pmid: 15573385].
3043 Morrison A, Levy R. Fraction of nursing home admissions attributable to urinary incontinence. Value Health. Jul–Aug. 2006;9(4):272-4. Not eligible outcomes. [pmid: 16903997].
3044 Mort J. Medications exacerbating urinary incontinence in the elderly. S D J Med. Oct. 1997;50(10):361-2. Comment. [pmid: 9360444].
3045 Mortensen N, Humphreys MS. The anal continence plug: a disposable device for patients with anorectal incontinence. Lancet. Aug 3. 1991;338(8762):295-7. Case-series. [pmid: 1677121].
3046 Mortensen S, Lose G, Thyssen H. Repeatability of cystometry and pressure-flow parameters in female patients. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):72-5. Case-series. [pmid: 12054185].
3047 Moss E, Toozs-Hobson P, Cardozo L, et al. A multicentre review of the tension-free vaginal tape procedure in clinical practice. J Obstet Gynaecol. Sep. 2002;22(5):519-22. Not eligible exposure. [pmid: 12521421].
3048 Mouritsen L, Bach P. Ultrasonic evaluation of bladder neck position and mobility: the influence of urethral catheter, bladder volume, and body position. Neurourol Urodyn. 1994;13(6):637-46. Case-series. [pmid: 7697055].
3049 Mouritsen L, Rasmussen A. Bladder neck mobility evaluated by vaginal ultrasonography. Br J Urol. Feb. 1993;71(2):166-71. Not eligible outcomes. [pmid: 8461949].
3050 Mouritsen L, Strandberg C. Vaginal ultrasonography versus colpo-cysto-urethrography in the evaluation of female urinary incontinence. Acta Obstet Gynecol Scand. Apr. 1994;73(4):338-42. Not eligible outcomes. [pmid: 8160543].
3051 Mouritsen L, Strandberg C, Frimodt-Moller C. Bladder neck anatomy and mobility: effect of vaginal ultrasound probe. Br J Urol. Dec. 1994;74(6):749-52. Not eligible outcomes. [pmid: 7827846].
3052 Movig KL, Leufkens HG, Belitser SV, et al. Selective serotonin reuptake inhibitor-induced urinary incontinence. Pharmacoepidemiol Drug Saf. Jun. 2002;11(4):271-9. Not eligible level of evidence. [pmid: 12138594].
3053 Mowschenson PM, Critchlow JF, Rosenberg SJ, et al. Factors favoring continence, the avoidance of a diverting ileostomy and small intestinal conservation in the ileoanal pouch operation. Surg Gynecol Obstet. Jul. 1993;177(1):17-26. Case-series. [pmid: 8391725].
3054 Mraz JP, Sutory M, Zerhau P. Simple flap valve for continent urinary diversion. Br J Urol. Sep. 1994;74(3):328-32. Case-series. [pmid: 7953265].
3055 Mueller C, Cain H. Comprehensive management of urinary incontinence through quality improvement efforts. Geriatr Nurs. Mar–Apr. 2002;23(2):82-7. No associative hypothesis tested. [pmid: 11956520].
3056 Mueller MH, Kreis ME, Gross ML, et al. Anorectal functional disorders in the absence of anorectal inflammation in patients with Crohn's disease. Br J Surg. Aug. 2002;89(8):1027-31. Not eligible outcomes. [pmid: 12153630].
3057 Mukamel DB, Watson NM, Meng H, et al. Development of a risk-adjusted urinary incontinence outcome measure of quality for nursing homes. Med Care. Apr. 2003;41(4):467-78. Not eligible outcomes. [pmid: 12665711].
3058 Mukherjee K, Constantine G. Urinary stress incontinence in obese women: tension-free vaginal tape is the answer. BJU Int. Dec. 2001;88(9):881-3. Not eligible target population. [pmid: 11851607].
3059 Mularczyk A, Basilisco G. Fecal incontinence induced by spontaneous internal anal sphincter relaxation: report of a case. Dis Colon Rectum. Jul. 2002;45(7):973-6. Case- Reports. [pmid: 12130889].
3060 Mulholland TL, Huynh PN, Huang RR, et al. Urinary incontinence after radical retropubic prostatectomy is not related to patient body mass index. Prostate Cancer Prostatic Dis. 2006;9(2):153-9. Not eligible level of evidence. [pmid: 16505832].
3061 Muller J, Seppi K, Stefanova N, et al. Freezing of gait in postmortem-confirmed atypical parkinsonism. Mov Disord. Sep. 2002;17(5):1041-5. Case-series. [pmid: 12360556].
3062 Muller N. WHO initiatives for the incontinent elderly. Ostomy Wound Manage. Nov–Dec. 1997;43(10):64-6. Review. [pmid: 9460437].
3063 Muller N. Promoting urinary health. Provider. Mar. 2002;28(3):51-3. Comment. [pmid: 11899600].
3064 Muller N. What Americans understand and how they are affected by bladder control problems: highlights of recent nationwide consumer research. Urol Nurs. Apr. 2005;25(2):109-15. Not eligible outcomes. [pmid: 15900979].
3065 Munchiando JF, Kendall K. Comparison of the effectiveness of two bowel programs for CVA patients. Rehabil Nurs. May–Jun. 1993;18(3):168-72. Case-series. [pmid: 8502842].
3066 Muncie HL Jr, Warren JW. Reasons for replacement of long-term urethral catheters: implications for randomized trials. J Urol. Mar. 1990;143(3):507-9. Not eligible outcomes. [pmid: 2406463].
3067 Munir N, Bunce C, Gelister J, et al. Outcome following TVT sling procedure: a comparison of outcome recorded by surgeons to that reported by their patients at a London district general hospital. Eur Urol. May. 2005;47(5):635-40. discussion 40. Case-series. [pmid: 15826755].
3068 Munoz Yague T, Alvarez Sanchez V, Ibanez Pinto A, et al. Clinical, anorectal manometry and surface electromyography in the study of patients with fecal incontinence. Rev Esp Enferm Dig 2003 Sep; 95(9):635–9, 29–34. Case-series
3069 Muqim RU, Naz T. Urethral diverticulum in female. J Coll Physicians Surg Pak. Jan. 2004;14(1):55-6. Case report. [pmid: 14764267].
3070 Murphy EL, Fridey J, Smith JW, et al. HTLV-associated myelopathy in a cohort of HTLV-I and HTLV-II-infected blood donors. The REDS investigators. Neurology. Feb. 1997;48(2):315-20. Not eligible outcomes. [pmid: 9040713].
3071 Murphy GP, Mettlin C, Menck H, et al. National patterns of prostate cancer treatment by radical prostatectomy: results of a survey by the American College of Surgeons Commission on Cancer. J Urol. Nov. 1994;152(5 Pt 2):1817-9. Not eligible level of evidence. [pmid: 7523727].
3072 Murphy KP, Kliever EM, Moore MJ. The voiding alert system: a new application in the treatment of incontinence. Arch Phys Med Rehabil. Aug. 1994;75(8):924-7. Case Reports. [pmid: 8053802].
3073 Murphy M, Culligan PJ, Arce CM, et al. Is the cough-stress test necessary when placing the tension-free vaginal tape?. Obstet Gynecol. Feb. 2005;105(2):319-24. Not eligible exposure. [pmid: 15684159].
3074 Murphy M, Culligan PJ, Arce CM, et al. Construct validity of the incontinence severity index. Neurourol Urodyn. 2006;25(5):418-23. Not eligible outcomes. [pmid: 16652379].
3075 Murphy S, Denman S, Bennett RG, et al. Methicillin-resistant Staphylococcus aureus colonization in a long-term-care facility. J Am Geriatr Soc. Mar. 1992;40(3):213-7. Not eligible outcomes. [pmid: 1538037].
3076 Murphy S, Rea D, O'Mahony J, et al. A comparison of the functional durability of the AMS 800 artificial urinary sphincter between cases with and without an underlying neurogenic aetiology. Ir J Med Sci. Jul–Sep. 2003;172(3):136-8. Case-series. [pmid: 14700117].
3077 Murray C, Goh JT, Fynes M, et al. Urinary and faecal incontinence following delayed primary repair of obstetric genital fistula. Bjog. Jul. 2002;109(7):828-32. Case-series. [pmid: 12135221].
3078 Mushkat Y, Bukovsky I, Langer R. Female urinary stress incontinence—does it have familial prevalence?. Am J Obstet Gynecol. Feb. 1996;174(2):617-9. Not eligible level of evidence. [pmid: 8623794].
3079 Muskat Y, Bukovsky I, Schneider D, et al. The use of scopolamine in the treatment of detrusor instability. J Urol. Dec. 1996;156(6):1989-90. Not eligible exposure. [pmid: 8911372].
3080 Musselman DM, Ford AP, Gennevois DJ, et al. A randomized crossover study to evaluate Ro 115–1240, a selective alpha1A/1L-adrenoceptor partial agonist in women with stress urinary incontinence. BJU Int. Jan. 2004;93(1):78-83. Not eligible exposure. [pmid: 14678373].
3081 Mustafa M, Wadie BS. Placard-shaped in situ vaginal wall sling for the treatment of stress urinary incontinence. Int J Urol. Feb. 2006;13(2):132-4. Not eligible target population. [pmid: 16563137].
3082 Mutone N, Brizendine E, Hale D. Factors that influence voiding function after the tension-free vaginal tape procedure for stress urinary incontinence. Am J Obstet Gynecol. Jun. 2003;188(6):1477-81. discussion 81–3. Case-series. [pmid: 12824981].
3083 Myers AH, Palmer MH, Engel BT, et al. Mobility in older patients with hip fractures: examining prefracture status, complications, and outcomes at discharge from the acute-care hospital. J Orthop Trauma. 1996;10(2):99-107. Not eligible outcomes. [pmid: 8932668].
3084 Myers DL, Arya LA, Friedman JH. Is urinary incontinence different in women with Parkinson's disease?. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):188-91. Not eligible level of evidence. [pmid: 10430013].
3085 Myers DL, LaSala CA. Conservative surgical management of Mersilene mesh suburethral sling erosion. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1424-8. discussion 8–9. Case-series. [pmid: 9855576].
3086 Myers DL, Lasala CA, Hogan JW, et al. The effect of posterior wall support defects on urodynamic indices in stress urinary incontinence. Obstet Gynecol. May. 1998;91(5 Pt 1):710-4. Not eligible outcomes. [pmid: 9572216].
3087 Myers DL, Peipert JF, Rosenblatt PL, et al. Patient satisfaction with laparoscopic Burch retropubic urethropexy. J Reprod Med. Nov. 2000;45(11):939-43. Case-series. [pmid: 11127109].
3088 Nacmias B, Tedde A, Guarnieri BM, et al. Analysis of apolipoprotein E, alpha1-antichymotrypsin and presenilin-1 genes polymorphisms in dementia caused by normal pressure hydrocephalus in man. Neurosci Lett. Jul 4. 1997;229(3):177-80. Not eligible outcomes. [pmid: 9237487].
3089 Nager C, Stanton S. Can HRT help incontinence?. Community Nurse. May. 1997;3(4):32-3. Comment. [pmid: 9451143].
3090 Naglie G, Radomski SB, Brymer C, et al. A randomized, double-blind, placebo controlled crossover trial of nimodipine in older persons with detrusor instability and urge incontinence. J Urol. Feb. 2002;167(2 Pt 1):586-90. Not eligible exposure. [pmid: 11792923].
3091 Naidu A, Lim YN, Barry C, et al. Transobturator tape for stress incontinence: the North Queensland experience. Aust N Z J Obstet Gynaecol. Oct. 2005;45(5):446-9. Case-series. [pmid: 16171486].
3092 Nair KP, Taly AB, Maheshwarappa BM, et al. Nontraumatic spinal cord lesions: a prospective study of medical complications during in-patient rehabilitation. Spinal Cord. Sep. 2005;43(9):558-64. Case-series. [pmid: 15824754].
3093 Nakagami G, Sanada H, Kitagawa A, et al. Incontinence induces stratum corneum vulnerability and impairs the skin barrier function in the perianal region. Dermatology. 2006;213(4):293-9. Not eligible outcomes. [pmid: 17135734].
3094 Nakai S, Yoshizawa H, Kobayashi S, et al. Anorectal and bladder function after sacrifice of the sacral nerves. Spine. Sep 1. 2000;25(17):2234-9. Case-reports. [pmid: 10973408].
3095 Nakamura T, Ishiko O, Hirai K, et al. Clinical evaluation of the Q-tip test in normal pregnant women. Gynecol Obstet Invest. 2001;51(2):92-5. Not eligible level of evidence. [pmid: 11223700].
3096 Nakanishi N, Tatara K, Shinsho F, et al. Mortality in relation to urinary and faecal incontinence in elderly people living at home. Age Ageing. May. 1999;28(3):301-6. Not eligible exposure. [pmid: 10475868].
3097 Nakayama Y, Tanaka A, Ohshiro S, et al. Extensive edema in the thalamus caused by thrombosed basilar artery aneurysm. Neurol Med Chir (Tokyo). May. 1998;38(5):274-7. Case-reports. [pmid: 9640962].
3098 Namiki S, Ishidoya S, Saito S, et al. Natural history of voiding function after radical retropubic prostatectomy. Urology. Jul. 2006;68(1):142-7. Not eligible exposure. [pmid: 16777193].
3099 Namiki S, Kuwahara M, Ioritani N, et al. An evaluation of urinary function after radical prostatectomy in Japanese men: concordance with definitions of urinary continence. BJU Int. Mar. 2005;95(4):530-3. Case series. [pmid: 15705074].
3100 Namiki S, Saito S, Ishidoya S, et al. Adverse effect of radical prostatectomy on nocturia and voiding frequency symptoms. Urology. Jul. 2005;66(1):147-51. Not eligible outcomes. [pmid: 15992905].
3101 Narayan P, Konety B, Aslam K, et al. Neuroanatomy of the external urethral sphincter: implications for urinary continence preservation during radical prostate surgery. J Urol. Feb. 1995;153(2):337-41. Not eligible target population. [pmid: 7815577].
3102 Nataluk EA, Assimos DG, Kroovand RL. Collagen injections for treatment of urinary incontinence secondary to intrinsic sphincter deficiency. J Endourol. Oct. 1995;9(5):403-6. Case-series. [pmid: 8580941].
3103 Nativ O, Levine S, Madjar S, et al. Incisionless per vaginal bone anchor cystourethropexy for the treatment of female stress incontinence: experience with the first 50 patients. J Urol. Nov. 1997;158(5):1742-4. Case-series. [pmid: 9334591].
3104 Natsume O, Kondo H, Cho M, et al. The impact of radical prostatectomy on patient well-being: a prospective urodynamic study focused on detrusor function. Hinyokika Kiyo. Jan. 2004;50(1):1-6. Case-series. [pmid: 15032007].
3105 Navarro M, Dotor E, Rivera F, et al. A Phase II study of preoperative radiotherapy and concomitant weekly irinotecan in combination with protracted venous infusion 5-fluorouracil, for resectable locally advanced rectal cancer. Int J Radiat Oncol Biol Phys. Sep 1. 2006;66(1):201-5. Not eligible outcomes. [pmid: 16814947].
3106 Nazarko L. Care of the elderly: incontinence through incompetence. Nurs Stand. Apr 28–May 4. 1993;7(32):52-3. Comment.
3107 Nazarko L. In search of relief. Nurs Times. Aug 7–13. 1996;92(32):68-70. Case Reports. [pmid: 8826424].
3108 Nazarko L. Educating Elsie. Nurs Times. Oct 22–28. 1997;93(43):68-71. Case Reports. [pmid: 9386525].
3109 Nazarko L. The whole story. Nurs Times 1997 Oct 22–28; 93(43):63–6, 8. Comment
3110 Nazarko L. Back to the future. Nurs Times 1998 Oct 21–27; 94(42):79–80, 3–4. Case Reports
3111 Nazarko L. Continence. Assess all areas. Nurs Times 1999 Feb 10–16; 95(6):68, 71–2. Case Reports
3112 Nazarko L. A new perspective on an old problem. Nurs Times. Jul 26–Aug 1. 2001;97(30):52-3. Secondary data analysis. [pmid: 11957958].
3113 Nazir M, Carlsen E, Jacobsen AF, et al. Is there any correlation between objective anal testing, rupture grade, and bowel symptoms after primary repair of obstetric anal sphincter rupture?: an observational cohort study. Dis Colon Rectum. Oct. 2002;45(10):1325-31. Not eligible outcomes. [pmid: 12394430].
3114 Nazir M, Carlsen E, Nesheim BI. Do occult anal sphincter injuries, vector volume manometry and delivery variables have any predictive value for bowel symptoms after first time vaginal delivery without third and fourth degree rupture? A prospective study. Acta Obstet Gynecol Scand. Aug. 2002;81(8):720-6. Case-series. [pmid: 12174155].
3115 N'Dow J, Leung HY, Marshall C, et al. Bowel dysfunction after bladder reconstruction. J Urol. May. 1998;159(5):1470-4. discussion 4–5. Case-series. [pmid: 9554335].
3116 Neal LJ. Rehab's role in incontinence treatment and ostomy care. Rehab Manag 2000 Jun–Jul; 13(5):28–30, 100. Comment
3117 Neale EJ. Abdominal hysterectomy after insertion of tension-free vaginal tape. Bjog. Jun. 2002;109(6):731-2. Case Reports. [pmid: 12118659].
3118 Nelson RL, Prasad ML, Pearl RK, et al. Inverted U-pouch construction for restoration of function in patients with failed straight ileoanal pull-throughs. Dis Colon Rectum. Nov. 1991;34(11):1040-2. Case Reports. [pmid: 1935470].
3119 Nesathurai S, Jessiman TL. L4–5 disk lesion resulting in back pain with bowel, bladder and sexual dysfunction without paraparesis. Spinal Cord. Mar. 1999;37(3):228-30. Case Reports. [pmid: 10213338].
3120 Nesbakken A, Nygaard K, Bull-Njaa T, et al. Bladder and sexual dysfunction after mesorectal excision for rectal cancer. Br J Surg. Feb. 2000;87(2):206-10. Case-series. [pmid: 10671929].
3121 Nesrallah LJ, Almeida FG, Dall'oglio MF, et al. Experience with the orthotopic ileal neobladder in women: a mid-term follow-up. BJU Int. May. 2005;95(7):1045-7. Case-series. [pmid: 15839929].
3122 Nesrallah LJ, Srougi M, Dall'Oglio MF. Orthotopic ileal neobladder: the influence of reservoir volume and configuration on urinary continence and emptying properties. BJU Int. Feb. 2004;93(3):375-8. Case-series. [pmid: 14764141].
3123 Neuman M. Low incidence of post-TVT genital prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):191-2. discussion 2. Case-reports. [pmid: 12955341].
3124 Neuman M. Trans vaginal tape readjustment after unsuccessful tension-free vaginal tape operation. Neurourol Urodyn. 2004;23(3):282-3. Case-series. [pmid: 15098228].
3125 Neumann C, Schmid H. Relationship between the degree of cardiovascular autonomic dysfunction and symptoms of neuropathy and other complications of diabetes mellitus. Braz J Med Biol Res. Jul. 1995;28(7):751-7. Not eligible target population. [pmid: 8580865].
3126 Neumann P, Blizzard L, Grimmer K, et al. Expanded paper towel test: an objective test of urine loss for stress incontinence. Neurourol Urodyn. 2004;23(7):649-55. Not eligible outcomes. [pmid: 15382187].
3127 Neumann PB, Grimmer KA, Grant RE, et al. Physiotherapy for female stress urinary incontinence: a multicentre observational study. Aust N Z J Obstet Gynaecol. Jun. 2005;45(3):226-32. Case-series. [pmid: 15904449].
3128 Newey ML, Sen PK, Fraser RD. The long-term outcome after central cord syndrome: a study of the natural history. J Bone Joint Surg Br. Aug. 2000;82(6):851-5. Case-series. [pmid: 10990310].
3129 Newman DK. Aging and the problem of urinary incontinence: AHCPR's 1996 clinical practice guidance. Urol Nurs. Dec. 1996;16(4):121-2. Guidance. [pmid: 9258051].
3130 Newman DK. What's new: the AHCPR guideline update on urinary incontinence. Ostomy Wound Manage 1996 Nov–Dec; 42(10):46–50, 2–4, 6 passim. Guideline
3131 Newman DK. Bladder control requires active management. J Womens Health. May. 1998;7(4):425-6. Comment. [pmid: 9611699].
3132 Newman DK. New treatment options for overactive bladder and incontinence. Director. Summer. 2002;10(3):74-6. Review. [pmid: 12116753].
3133 Newman DK. Report of a mail survey of women with bladder control disorders. Urol Nurs. Dec. 2004;24(6):499-507. Not eligible outcomes. [pmid: 15658736].
3134 Newman DK, Gaines T, Snare E. Innovation in bladder assessment: use of technology in extended care. J Gerontol Nurs. Dec. 2005;31(12):33-41. quiz 2–3. Case-series.
3135 Newman DK, Wallace J, Blackwood N, et al. Promoting healthy bladder habits for seniors. Ostomy Wound Manage 1996 Nov–Dec; 42(10):18–22, 4–5, 8. No associative hypothesis tested
3136 Ng C, Prott G, Rutkowski S, et al. Gastrointestinal symptoms in spinal cord injury: relationships with level of injury and psychologic factors. Dis Colon Rectum. Aug. 2005;48(8):1562-8. Not eligible target population. [pmid: 15981066].
3137 Ng CC, Lee LC, Han WH. Use of three-dimensional ultrasound scan to assess the clinical importance of midurethral placement of the tension-free vaginal tape (TVT) for treatment of incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):220-5. Case-series. [pmid: 15875238].
3138 Ng RK, Murray A. Can we afford to take short cuts in the management of stress urinary incontinence?. Singapore Med J. Apr. 1993;34(2):121-4. Case-series. [pmid: 8266149].
3139 Ngninkeu BN, van Heugen G, di Gregorio M, et al. Laparoscopic artificial urinary sphincter in women for type III incontinence: preliminary results. Eur Urol. Jun. 2005;47(6):793-7. discussion 7. Case-series. [pmid: 15925075].
3140 Nguyen A, Mahoney S, Minor L, et al. A simple objective method of adjusting sling tension. J Urol. Nov. 1999;162(5):1674-6. Case-series. [pmid: 10524895].
3141 Nguyen JK, Bhatia NN. Risk of recurrent stress incontinence in women undergoing the combined modified pereyra procedure and transvaginal sacrospinous ligament vault suspension. Urology. Dec. 2001;58(6):947-52. Case-series. [pmid: 11744465].
3142 Nguyen JK, Bhatia NN. Resolution of motor urge incontinence after surgical repair of pelvic organ prolapse. J Urol. Dec. 2001;166(6):2263-6. Case-series. [pmid: 11696748].
3143 Nguyen JK, Gunn GC, Bhatia NN. The effect of patient position on leak-point pressure measurements in women with genuine stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(1):9-14. Not eligible exposure. [pmid: 11999213].
3144 Nguyen JN. Tape mobilization for urinary retention after tension-free vaginal tape procedures. Urology. Sep. 2005;66(3):523-6. Case-series. [pmid: 16140070].
3145 Nguyen JN, Yazdany T, Burchette RJ. Urodynamic evaluation of urethral competency in women with posterior vaginal support defects. Urology. Jan. 2007;69(1):87-90. Not eligible outcomes. [pmid: 17270623].
3146 Nguyen TT, Maartens NF. Images in neuroscience: urge incontinence and an abnormal patch of skin. J Clin Neurosci 2005 Apr; 12(3):271–2, 95. Case report
3147 Nicholls RJ, Gilbert JM. Surgical correction of the efferent ileal limb for disordered defaecation following restorative proctocolectomy with the S ileal reservoir. Br J Surg. Feb. 1990;77(2):152-4. Case-series. [pmid: 2317674].
3148 Nichols CM, Lamb EH, Ramakrishnan V. Differences in outcomes after third- versus fourth-degree perineal laceration repair: a prospective study. Am J Obstet Gynecol. Aug. 2005;193(2):530-4. discussion 4–6. Case-series. [pmid: 16098885].
3149 Nicita G. A new operation for genitourinary prolapse. J Urol. Sep. 1998;160(3 Pt 1):741-5. Case-series. [pmid: 9720536].
3150 Nickless R, Burke N, Bolton T. Using ultrasound to assess bladder function in aged care rehabilitation. Aust Nurs J 2002 May; 9(10):suppl 1–3. Secondary data analysis
3151 Nielsen KK, Kromann-Andersen B, Jacobsen H, et al. The urethral plug: a new treatment modality for genuine urinary stress incontinence in women. J Urol. Nov. 1990;144(5):1199-202. Case-series. [pmid: 2231895].
3152 Nielsen MB, Buron B, Christiansen J, et al. Defecographic findings in patients with anal incontinence and constipation and their relation to rectal emptying. Dis Colon Rectum. Sep. 1993;36(9):806-9. Not associative hypothesis tested. [pmid: 8375220].
3153 Nielsen MB, Dammegaard L, Pedersen JF. Endosonographic assessment of the anal sphincter after surgical reconstruction. Dis Colon Rectum. May. 1994;37(5):434-8. Case-series. [pmid: 8181403].
3154 Nielsen MB, Hauge C, Pedersen JF, et al. Endosonographic evaluation of patients with anal incontinence: findings and influence on surgical management. AJR Am J Roentgenol. Apr. 1993;160(4):771-5. Not eligible outcomes. [pmid: 8456663].
3155 Nielsen MB, Hauge C, Rasmussen OO, et al. Anal endosonographic findings in the follow-up of primarily sutured sphincteric ruptures. Br J Surg. Feb. 1992;79(2):104-6. Case-series. [pmid: 1555052].
3156 Nielsen MB, Rasmussen OO, Pedersen JF, et al. Risk of sphincter damage and anal incontinence after anal dilatation for fissure-in-ano. An endosonographic study. Dis Colon Rectum. Jul. 1993;36(7):677-80. Case-series. [pmid: 8348852].
3157 Niemczyk P, Klutke JJ, Carlin BI, et al. United States experience with tension-free vaginal tape procedure for urinary stress incontinence: assessment of safety and tolerability. Tech Urol. Dec. 2001;7(4):261-5. Case-series. [pmid: 11763484].
3158 Nieuwenhuijzen JA, Meinhardt W, Horenblas S. Clinical outcomes after sexuality preserving cystectomy and neobladder (prostate sparing cystectomy) in 44 patients. J Urol. Apr. 2005;173(4):1314-7. Case-series. [pmid: 15758788].
3159 Niewijk AH, Weijts WB. Effects of a multi-media course on urinary incontinence. Patient Educ Couns. Jan. 1997;30(1):95-103. Not eligible level of evidence. [pmid: 9110836].
3160 Nikiteas N, Korsgen S, Kumar D, et al. Audit of sphincter repair. Factors associated with poor outcome. Dis Colon Rectum. Oct. 1996;39(10):1164-70. Case-series. [pmid: 8831535].
3161 Nill TG, Peller PA, Kropp KA. Management of urinary incontinence by bladder tube urethral lengthening and submucosal reimplantation. J Urol. Aug. 1990;144(2 Pt 2):559-61. discussion 62–3. Case-series. [pmid: 2374240].
3162 Nilsson CG. Effectiveness of the conveen continence guard (a disposable vaginal device) in the treatment of complicated female stress incontinence. Acta Obstet Gynecol Scand. Dec. 2000;79(12):1052-5. Not eligible target population. [pmid: 11130086].
3163 Nilsson CG, Kuuva N. The tension-free vaginal tape procedure is successful in the majority of women with indications for surgical treatment of urinary stress incontinence. Bjog. Apr. 2001;108(4):414-9. Case-series. [pmid: 11305550].
3164 Nilsson CG, Kuuva N, Falconer C, et al. Long-term results of the tension-free vaginal tape (TVT) procedure for surgical treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S5-8. Case-series. [pmid: 11450979].
3165 Nilsson CG, Lukkari E, Haarala M, et al. Comparison of a 10-mg controlled release oxybutynin tablet with a 5-mg oxybutynin tablet in urge incontinent patients. Neurourol Urodyn. 1997;16(6):533-42. Not eligible exposure. [pmid: 9353802].
3166 Nissenkorn I, Richter S, Slutzker D. A simple, self-retaining intraurethral catheter for treatment of prostatic obstruction. Eur Urol. 1990;18(4):286-9. Case-series. [pmid: 1705227].
3167 Nitahara KS, Aboseif S, Tanagho EA. Long-term results of colpocystourethropexy for persistent or recurrent stress urinary incontinence. J Urol. Jul. 1999;162(1):138-41. Case-series. [pmid: 10379757].
3168 Nitti VW, Bregg KJ, Sussman EM, et al. The Raz bladder neck suspension in patients 65 years old and older. J Urol. Apr. 1993;149(4):802-7. Case-series. [pmid: 8455244].
3169 Nitti VW, Carlson KV, Blaivas JG, et al. Early results of pubovaginal sling lysis by midline sling incision. Urology. Jan. 2002;59(1):47-51. discussion -2. Not eligible exposure. [pmid: 11796279].
3170 Nitti VW, Combs AJ. Correlation of Valsalva leak point pressure with subjective degree of stress urinary incontinence in women. J Urol. Jan. 1996;155(1):281-5. Not eligible outcomes. [pmid: 7490856].
3171 Nitz NM, Jumadilova Z, Darkow T, et al. Medical costs after initiation of drug treatment for overactive bladder: effects of selection bias on cost estimates. Am J Manag Care. Jul. 2005;11(4 Suppl):S130-9. Not eligible outcomes. [pmid: 16161386].
3172 Nixon E. Continence. Easing the social stress. Nurs Times. Dec 13–19. 1995;91(50):60. No associative hypothesis tested. [pmid: 8559688].
3173 Nobili F, Copello F, Buffoni F, et al. Regional cerebral blood flow and prognostic evaluation in Alzheimer's disease. Dement Geriatr Cogn Disord. Mar–Apr. 2001;12(2):89-97. Not eligible exposure. [pmid: 11173880].
3174 Nobili F, Copello F, Vitali P, et al. Timing of disease progression by quantitative EEG in Alzheimer' s patients. J Clin Neurophysiol. Nov. 1999;16(6):566-73. Case-series. [pmid: 10600024].
3175 Noble JM, Canoll P, Honig LS. Brain tumor-associated dementia. Sci Aging Knowledge Environ. Aug 24. 2005;2005(34):dn2. Case- Reports. [pmid: 16120848].
3176 Nochajski TH, Burns PA, Pranikoff K, et al. Dimensions of urine loss among older women with genuine stress incontinence. Neurourol Urodyn. 1993;12(3):223-33. Not eligible outcomes. [pmid: 8330045].
3177 Noguchi M, Eguchi Y, Ichiki J, et al. Therapeutic efficacy of clenbuterol for urinary incontinence after radical prostatectomy. Int J Urol. Sep. 1997;4(5):480-3. Case-series. [pmid: 9354950].
3178 Noguchi M, Noda S, Nakashima O, et al. Suspension technique improves rapid recovery of urinary continence following radical retropubic prostatectomy. Kurume Med J. 2004;51(34):245-51. Not eligible exposure. [pmid: 15682831].
3179 Noguchi M, Shimada A, Nakashima O, et al. Urodynamic evaluation of a suspension technique for rapid recovery of continence after radical retropubic prostatectomy. Int J Urol. Apr. 2006;13(4):373-8. Case-series. [pmid: 16734853].
3180 Noh C, Kshirsagar A, Mohler JL. Outcomes after radical retropubic prostatectomy. Urology. Feb. 2003;61(2):412-6. Case series. [pmid: 12597958].
3181 Nomura S, Ishido T, Tanaka K, et al. Augmentation ileocystoplasty in patients with neurogenic bladder due to spinal cord injury or spina bifida. Spinal Cord. Jan. 2002;40(1):30-3. Case-series. [pmid: 11821967].
3182 Norderval S, Oian P, Revhaug A, et al. Anal incontinence after obstetric sphincter tears: outcome of anatomic primary repairs. Dis Colon Rectum. May. 2005;48(5):1055-61. Case-series. [pmid: 15785888].
3183 Nordstrom G, Nyman CR, Theorell T. Psychosocial adjustment and general state of health in patients with ileal conduit urinary diversion. Scand J Urol Nephrol. 1992;26(2):139-47. Case-series. [pmid: 1626203].
3184 Nordstrom GM, Nyman CR. Male and female sexual function and activity following ileal conduit urinary diversion. Br J Urol. Jul. 1992;70(1):33-9. Case-series.
3185 Norris A, Scerri A, Powell M. Quality of anaesthesia for insertion of tension-free vaginal tape using local analgesia and sedation. Eur J Anaesthesiol. Nov. 2001;18(11):755-8. Not eligible exposure. [pmid: 11580782].
3186 Norton C. Continence. Continent's provision. Nurs Times. Oct 28–Nov 3. 1992;88(44):76-8. Comment. [pmid: 1454576].
3187 Norton C. Incontinence in old age. Nurs Elder. Jul–Aug. 1992;4(4):17-8. [pmid: 1388917].
3188 Norton C. Asking simple questions: promoting continence (repeat) (continuing education credit). Nurs Stand. Jul 31. 1996;10(45 Suppl Nu):5-17. quiz 21–5. No associative hypothesis tested.
3189 Norton C. Providing appropriate services for continence: an overview. Nurs Stand. Jun 26. 1996;10(40):41-5. Review. [pmid: 8718019].
3190 Norton C. Faecal incontinence in adults. Nurs Stand. Aug 6. 1997;11(46):49-54. quiz 5–6. Comment. [pmid: 9325988].
3191 Norton C, Brown J, Thomas E. Continence: a phone call away. Nurs Stand. Mar 15–21. 1995;9(25):22-3. Comment. [pmid: 7727239].
3192 Norton C, Burch J, Kamm MA. Patients' views of a colostomy for fecal incontinence. Dis Colon Rectum. May. 2005;48(5):1062-9. Not eligible outcomes. [pmid: 15868244].
3193 Norton C, Chelvanayagam S. A nursing assessment tool for adults with fecal incontinence. J Wound Ostomy Continence Nurs. Sep. 2000;27(5):279-91. No associative hypothesis tested. [pmid: 10999967].
3194 Norton C, Fader M. Continence management. Elder Care. Nov–Dec. 1994;6(6):23-7. Comment. [pmid: 7804174].
3195 Norton C, Kamm MA. Outcome of biofeedback for faecal incontinence. Br J Surg. Sep. 1999;86(9):1159-63. Case-series. [pmid: 10504370].
3196 Norton C, Kamm MA. Anal plug for faecal incontinence. Colorectal Dis. Sep. 2001;3(5):323-7. No associative hypothesis tested. [pmid: 12790954].
3197 Norton P, Karram M, Wall LL, et al. Randomized double-blind trial of terodiline in the treatment of urge incontinence in women. Obstet Gynecol. Sep. 1994;84(3):386-91. Not eligible exposure. [pmid: 8058236].
3198 Nouira Y, Feki W, Rhouma SB, et al. Vesicouterine fistula as a complication of forceps delivery: a case report. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):512-4. Case Reports. [pmid: 15809774].
3199 Novielli KD, Simpson Z, Hua G, et al. Urinary incontinence in primary care: a comparison of older African-American and Caucasian women. Int Urol Nephrol. 2003;35(3):423-8. Not eligible level of evidence. [pmid: 15160551].
3200 Nuotio M, Jylha M, Luukkaala T, et al. Health problems associated with lower urinary tract symptoms in older women. A population-based survey. Scand J Prim Health Care. Dec. 2005;23(4):209-14. Not eligible outcomes. [pmid: 16272068].
3201 Nyaruhucha CN, Msuya JM, Matrida E. Nutritional status, functional ability and food habits of institutionalised and non-institutionalised elderly people in Morogoro Region, Tanzania. East Afr Med J. May. 2004;81(5):248-53. Case-series. [pmid: 15508339].
3202 Nyberg L, Gustafson Y. Fall prediction index for patients in stroke rehabilitation. Stroke. Apr. 1997;28(4):716-21. Not eligible outcomes. [pmid: 9099185].
3203 Nygaard I, DeLancey JO, Arnsdorf L, et al. Exercise and incontinence. Obstet Gynecol. May. 1990;75(5):848-51. Question 2. [pmid: 2325968].
3204 Nygaard I, Holcomb R. Reproducibility of the seven-day voiding diary in women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(1):15-7. Not eligible outcomes. [pmid: 10738929].
3205 Nygaard I, Zmolek G. Exercise pad testing in continent exercisers: reproducibility and correlation with voided volume, pyridium staining, and type of exercise. Neurourol Urodyn. 1995;14(2):125-9. Not eligible outcomes. [pmid: 7780439].
3206 Nygaard IE. Does prolonged high-impact activity contribute to later urinary incontinence? A retrospective cohort study of female Olympians. Obstet Gynecol. Nov. 1997;90(5):718-22. Not eligible level of evidence. [pmid: 9351751].
3207 Nygaard IE, Glowacki C, Saltzman CL. Relationship between foot flexibility and urinary incontinence in nulliparous varsity athletes. Obstet Gynecol. Jun. 1996;87(6):1049-51. Case-series. [pmid: 8649689].
3208 Nygaard IE, Thompson FL, Svengalis SL, et al. Urinary incontinence in elite nulliparous athletes. Obstet Gynecol. Aug. 1994;84(2):183-7. Not eligible level of evidence. [pmid: 8041527].
3209 Oberwalder M, Dinnewitzer A, Baig MK, et al. The association between late-onset fecal incontinence and obstetric anal sphincter defects. Arch Surg. Apr. 2004;139(4):429-32. Not eligible exposure. [pmid: 15078712].
3210 Oberwalder M, Thaler K, Baig MK, et al. Anal ultrasound and endosonographic measurement of perineal body thickness: a new evaluation for fecal incontinence in females. Surg Endosc. Apr. 2004;18(4):650-4. Not eligible outcomes. [pmid: 15026922].
3211 O'Boyle AL, O'Boyle JD, Place RJ. An active duty woman with anal incontinence after vaginal delivery: an elusive diagnosis. Mil Med. Dec. 2004;169(12):966-7. Case-reports. [pmid: 15646187].
3212 O'Brien J. Evaluating primary care interventions for incontinence. Nurs Stand. Feb 28. 1996;10(23):40-3. Case-series. [pmid: 8695463].
3213 O'Brien PE, Skinner S. Restoring control: the Acticon Neosphincter artificial bowel sphincter in the treatment of anal incontinence. Dis Colon Rectum. Sep. 2000;43(9):1213-6. Case-series. [pmid: 11005485].
3214 O'Connell B, Hanna B, Bailey S, et al. The nature and severity of urinary incontinence in post-natal women. Contemp Nurse. Oct. 2002;13(23):158-68. Not eligible level of evidence. [pmid: 16116771].
3215 O'Connell HE, McGuire EJ, Aboseif S, et al. Transurethral collagen therapy in women. J Urol. Oct. 1995;154(4):1463-5. Case-series. [pmid: 7658560].
3216 O'Connell-Gifford E. Contact dermatitis complicated by environment. Ostomy Wound Manage. Sep. 2000;46(9):16-7. Case- Reports. [pmid: 11189537].
3217 O'Connor JJ. Brief report: evaluation of fecal incontinence using rectal ultrasound. Md Med J. Apr. 1996;45(4):308-9. Comment. [pmid: 8775671].
3218 O'Connor RC, Stapp EC, Donnellan SM, et al. Long-term results of suprapubic bladder neck closure for treatment of the devastated outlet. Urology. Aug. 2005;66(2):311-5. Case-series. [pmid: 16040086].
3219 O'Donnell BF, Drachman DA, Barnes HJ, et al. Incontinence and troublesome behaviors predict institutionalization in dementia. J Geriatr Psychiatry Neurol. Jan–Mar. 1992;5(1):45-52. Not eligible outcomes. [pmid: 1571074].
3220 O'Donnell M, Viktrup L, Hunskaar S. The role of general practitioners in the initial management of women with urinary incontinence in France, Germany, Spain and the UK. Eur J Gen Pract. 2007;13(1):20-6. Not eligible level of evidence. [pmid: 17366290].
3221 O'Donnell PD, Beck C. Urinary incontinence volume patterns in elderly inpatient men. Urology. Aug. 1991;38(2):128-31. Case-series. [pmid: 1877127].
3222 O'Donnell PD, Brookover T, Hewett M, et al. Continence level following radical prostatectomy. Urology. Dec. 1990;36(6):511-2. Case-series. [pmid: 2247919].
3223 O'Donnell PD, Doyle R. Biofeedback therapy technique for treatment of urinary incontinence. Urology. May. 1991;37(5):432-6. Comment. [pmid: 2024391].
3224 Oefelein MG. Prospective predictors of urinary continence after anatomical radical retropubic prostatectomy: a multivariate analysis. World J Urol. Oct. 2004;22(4):267-71. Case-series. [pmid: 14727136].
3225 Oesterling JE, Gearhart JP. Utilization of ileal conduit in construction of continent urinary reservoir. Urology. Jul. 1990;36(1):15-9. Case Reports. [pmid: 2368225].
3226 Oettling G, Franz HB. Mapping of androgen, estrogen and progesterone receptors in the anal continence organ. Eur J Obstet Gynecol Reprod Biol. Apr. 1998;77(2):211-6. Not eligible outcomes. [pmid: 9578281].
3227 O'Flynn KJ, Murphy R, Thomas DG. Neurogenic bladder dysfunction in lumbar intervertebral disc prolapse. Br J Urol. Jan. 1992;69(1):38-40. Case-series. [pmid: 1737251].
3228 O'Flynn KJ, Thomas DG. Artificial urinary sphincter insertion in congenital neuropathic bladder. Br J Urol. Feb. 1991;67(2):155-7. Case-series. [pmid: 2004226].
3229 Oge O, Tekgul S, Ergen A, et al. Urothelium-preserving augmentation cystoplasty covered with a peritoneal flap. BJU Int. May. 2000;85(7):802-5. Not eligible target population. [pmid: 10792156].
3230 Ogundipe A, Rosenzweig BA, Karram MM, et al. Modified suburethral sling procedure for treatment of recurrent or severe stress urinary incontinence. Surg Gynecol Obstet. Aug. 1992;175(2):173-6. Case-series. [pmid: 1636142].
3231 Oh HS, Kim MK, Seo WS. Effectiveness of a behavioral intervention program for urinary incontinence in a community setting. Taehan Kanho Hakhoe Chi. Dec. 2005;35(8):1476-84. Not eligible target population. [pmid: 16415628].
3232 Oh SJ, Hong SK, Son H, et al. Quality of life and disease severity in Korean women with stress urinary incontinence. Urology. Jul. 2005;66(1):69-73. Not eligible outcomes. [pmid: 15992875].
3233 Oh SJ, Ku JH. Comparison of three disease-specific quality-of-life questionnaires (Bristol Female Lower Urinary Tract Symptoms, Incontinence Quality of Life and King's Health Questionnaire) in women with stress urinary incontinence. Scand J Urol Nephrol. 2007;41(1):66-71. Not eligible exposure. [pmid: 17366105].
3234 Oh SJ, Ku JH, Hong SK, et al. Factors influencing self-perceived disease severity in women with stress urinary incontinence combined with or without urge incontinence. Neurourol Urodyn. 2005;24(4):341-7. Not eligible outcomes. [pmid: 15791635].
3235 Ohkawa A, Kondo A, Takei M, et al. Tension-free vaginal tape surgery for stress urinary incontinencne: a prospective multicentered study in Japan. Int J Urol. Jun. 2006;13(6):738-42. Case-series. [pmid: 16834653].
3236 Ojanuga D. Preventing birth injury among women in Africa: case studies in northern Nigeria. Am J Orthopsychiatry. Oct. 1991;61(4):533-9. Case-series. [pmid: 1746628].
3237 Ojdeby G, Claezon A, Brekkan E, et al. Urinary incontinence and sexual impotence after radical prostatectomy. Scand J Urol Nephrol. Dec. 1996;30(6):473-7. Case-series. [pmid: 9008028].
3238 Okada Y, Shichiri Y, Terai A, et al. Management of late complications of continent urinary diversion using the Kock pouch and the Indiana pouch procedures. Int J Urol. Sep. 1996;3(5):334-9. Case- series. [pmid: 8886907].
3239 O'Keefe EA, Talley NJ, Zinsmeister AR, et al. Bowel disorders impair functional status and quality of life in the elderly: a population-based study. J Gerontol A Biol Sci Med Sci. Jul. 1995;50(4):M184-9. Not eligible target population. [pmid: 7614239].
3240 Okonkwo JE, Obionu CO, Obiechina NJ. Factors contributing to urinary incontinence and pelvic prolapse in Nigeria. Int J Gynaecol Obstet. Sep. 2001;74(3):301-3. Not eligible level of evidence. [pmid: 11543758].
3241 Oladokun A, Babarinsa IA, Adewole IF. The deficient perineum: oblique presentation of a clinically obvious anomaly. Afr J Med Med Sci. Sep. 2002;31(3):267-9. Case-series. [pmid: 12751570].
3242 Olagne E, Baulieux J, de la Roche E, et al. Functional results of delayed coloanal anastomosis after preoperative radiotherapy for lower third rectal cancer. J Am Coll Surg. Dec. 2000;191(6):643-9. Case-series. [pmid: 11129813].
3243 Olah KS. Vaginal colposuspension: a new approach to an established continence procedure. J Obstet Gynaecol. Nov. 2003;23(6):687-8. Case Reports. [pmid: 14617493].
3244 Oldbury M. Continence. Hard won comfort. Nurs Times. Mar 25–31. 1992;88(13):86. Case Reports. [pmid: 1297105].
3245 O'Leary MP, Gee WF, Holtgrewe HL, et al. 1999 American Urological Association Gallup Survey: changes in physician practice patterns, treatment of incontinence and bladder cancer, and impact of managed care. J Urol. Oct. 2000;164(4):1311-6. Not eligible outcomes. [pmid: 10992396].
3246 Oliveira L, Pfeifer J, Wexner SD. Physiological and clinical outcome of anterior sphincteroplasty. Br J Surg. Apr. 1996;83(4):502-5. Case-series. [pmid: 8665241].
3247 Oliveira L, Reissman P, Nogueras J, et al. Laparoscopic creation of stomas. Surg Endosc. Jan. 1997;11(1):19-23. Case-series. [pmid: 8994982].
3248 Oliver JR, Wheeless CR Jr, Fakhoury G. Correction of incontinent ileocolic urostomy with Kock's nipple valve. Gynecol Oncol. Nov. 1991;43(2):178-81. Case Reports. [pmid: 1743562].
3249 Olopade FA, Norman A, Blake P, et al. A modified Inflammatory Bowel Disease questionnaire and the Vaizey Incontinence questionnaire are simple ways to identify patients with significant gastrointestinal symptoms after pelvic radiotherapy. Br J Cancer. May 9. 2005;92(9):1663-70. Not eligible outcomes. [pmid: 15856043].
3250 Olson JK. Offsetting natural ‘poisons’. Incontinent residents require vigilant, gentle skin care. Contemp Longterm Care. Aug. 2001;24(8):17. Comment. [pmid: 11496700].
3251 O'Malley KJ, Hickey DP, Kapoor A, et al. Artificial urinary sphincter insertion in renal transplant recipients. Urology. Nov. 1999;54(5):923. Case Reports.
3252 O'Meara B. Continence. Hidden dangers. Nurs Times. Aug 4–10. 1999;95(31):70-3. News. [pmid: 10569026].
3253 Onaitis M, Ludwig K, Perez-Tamayo A, et al. The Kraske procedure: a critical analysis of a surgical approach for mid-rectal lesions. J Surg Oncol. Sep 1. 2006;94(3):194-202. Not eligible exposure. [pmid: 16900535].
3254 Ong NC, Dwyer PL. Labial fusion causing voiding difficulty and urinary incontinence. Aust N Z J Obstet Gynaecol. Aug. 1999;39(3):391-3. Case-reports. [pmid: 10554966].
3255 Onishi J, Suzuki Y, Umegaki H, et al. Behavioral, psychological and physical symptoms in group homes for older adults with dementia. Int Psychogeriatr. Mar. 2006;18(1):75-86. Question 1. [pmid: 16388705].
3256 Onishi J, Suzuki Y, Umegaki H, et al. Influence of behavioral and psychological symptoms of dementia (BPSD) and environment of care on caregivers' burden. Arch Gerontol Geriatr. Sep–Oct. 2005;41(2):159-68. Not eligible outcomes. [pmid: 16085067].
3257 Onur R, Singla A. Solvent-dehydrated cadaveric dermis: a new allograft for pubovaginal sling surgery. Int J Urol. Sep. 2005;12(9):801-5. Not eligible target population. [pmid: 16201975].
3258 Ooi BS, Ho YH, Eu KW, et al. Management of anorectal foreign bodies: a cause of obscure anal pain. Aust N Z J Surg. Dec. 1998;68(12):852-5. Case-series. [pmid: 9885867].
3259 Oom DM, Gosselink MP, Van Dijl VR, et al. Puborectal sling interposition for the treatment of rectovaginal fistulas. Tech Coloproctol. Jul. 2006;10(2):125-30. discussion 30. Case-series. [pmid: 16773287].
3260 Oostra K, Everaert K, Van Laere M. Urinary incontinence in brain injury. Brain Inj. Jun. 1996;10(6):459-64. Case-series. [pmid: 8816099].
3261 Oot-Giromini BA. Pressure ulcer prevalence, incidence and associated risk factors in the community. Decubitus. Sep. 1993;6(5):24-32. Not eligible outcomes. [pmid: 8286017].
3262 Ordonez E, Zivkovic F, Moser F, et al. Inadvertent ureteral catheterizaion with a microtip catheter at cystometry. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(3):184-5. Not eligible exposure. [pmid: 9745979].
3263 Ordorica R, Stein B. Incontinence: defining the problem. R I Med. Aug. 1994;77(8):262-3. Comment. [pmid: 7949427].
3264 Ordorica RC, Masel J, Seigne J, et al. Evaluation and management of mechanical dysfunction in continent colonic urinary reservoirs. J Urol. Jun. 2000;163(6):1679-84. Not eligible outcomes. [pmid: 10799159].
3265 Orkin BA, Soper NJ, Kelly KA, et al. Influence of sleep on anal sphincteric pressure in health and after ileal pouch-anal anastomosis. Dis Colon Rectum. Feb. 1992;35(2):137-44. Not eligible outcomes. [pmid: 1735315].
3266 Orovan WL, Davis IR. Kock to urethra: continent functional bladder replacement. Can J Surg. Apr. 1990;33(2):91-4. Case-series. [pmid: 2268818].
3267 Orr A, McVean RJ, Webb AK, et al. Questionnaire survey of urinary incontinence in women with cystic fibrosis. Bmj. Jun 23. 2001;322(7301):1521. Not eligible level of evidence. [pmid: 11420273]. [pmcid: 33391].
3268 Orrom WJ, Miller R, Cornes H, et al. Comparison of anterior sphincteroplasty and postanal repair in the treatment of idiopathic fecal incontinence. Dis Colon Rectum. Apr. 1991;34(4):305-10. Not eligible target population. [pmid: 2007347].
3269 Orrom WJ, Wong WD, Rothenberger DA, et al. Evaluation of an air-filled microballoon and mini-transducer in the clinical practice of anorectal manometry. Preliminary communication. Dis Colon Rectum. Jul. 1990;33(7):594-7. Not eligible outcomes. [pmid: 2361428].
3270 Ortiz H, Armendariz P, DeMiguel M, et al. Complications and functional outcome following artificial anal sphincter implantation. Br J Surg. Jul. 2002;89(7):877-81. Case-series. [pmid: 12081737].
3271 Ortiz H, Armendariz P, DeMiguel M, et al. Prospective study of artificial anal sphincter and dynamic graciloplasty for severe anal incontinence. Int J Colorectal Dis. Jul. 2003;18(4):349-54. Not eligible target population. [pmid: 12774251].
3272 Ortiz H, Marzo J. Endorectal flap advancement repair and fistulectomy for high trans-sphincteric and suprasphincteric fistulas. Br J Surg. Dec. 2000;87(12):1680-3. Case-series. [pmid: 11122184].
3273 Ortiz H, Marzo J, Armendariz P, et al. Quality of life assessment in patients with chronic anal fissure after lateral internal sphincterotomy. Br J Surg. Jul. 2005;92(7):881-5. Case-series. [pmid: 15892153].
3274 Osborne M. Iye Sowodie's “Gladdie, Gladdie” day. Mercy Ships treats women made incontinent by birth injuries. Midwifery Today Int Midwife 2006 Winter; (80):60–1. Comment
3275 Osterberg A, Edebol Eeg-Olofsson K, Graf W. Results of surgical treatment for faecal incontinence. Br J Surg. Nov. 2000;87(11):1546-52. Case-series. [pmid: 11091244].
3276 Osterberg A, Graf W, Edebol Eeg-Olofsson K, et al. Results of neurophysiologic evaluation in fecal incontinence. Dis Colon Rectum. Sep. 2000;43(9):1256-61. Not eligible outcomes. [pmid: 11005493].
3277 Osterberg A, Graf W, Eeg-Olofsson K, et al. Is electrostimulation of the pelvic floor an effective treatment for neurogenic faecal incontinence?. Scand J Gastroenterol. Mar. 1999;34(3):319-24. Case-series. [pmid: 10232880].
3278 Osterberg A, Graf W, Holmberg A, et al. Long-term results of anterior levatorplasty for fecal incontinence. A retrospective study. Dis Colon Rectum. Jun. 1996;39(6):671-4. discussion 4–5. Case-series. [pmid: 8646955].
3279 Osterberg A, Graf W, Karlbom U, et al. Evaluation of a questionnaire in the assessment of patients with faecal incontinence and constipation. Scand J Gastroenterol. Jun. 1996;31(6):575-80. Not eligible outcomes. [pmid: 8789896].
3280 Osterberg A, Graf W, Pahlman L. The longitudinal high-pressure zone profile in patients with fecal incontinence. Am J Gastroenterol. Oct. 1999;94(10):2966-71. Not eligible outcomes. [pmid: 10520853].
3281 Osterweil D, Martin M, Syndulko K. Predictors of skilled nursing placement in a multilevel long-term-care facility. J Am Geriatr Soc. Feb. 1995;43(2):108-12. Not eligible exposure. [pmid: 7836633].
3282 Ostrzenski A, Osborne NG, Ostrzenska K. Method for diagnosing paravaginal defects using contrast ultrasonographic technique. J Ultrasound Med. Oct. 1997;16(10):673-7. Not eligible outcomes. [pmid: 9323672].
3283 O'Sullivan R, Karantanis E, Stevermuer TL, et al. Definition of mild, moderate and severe incontinence on the 24-hour pad test. Bjog. Aug. 2004;111(8):859-62. Not eligible outcomes. [pmid: 15270937].
3284 O'Sullivan R, Simons A, Prashar S, et al. Is objective cure of mild undifferentiated incontinence more readily achieved than that of moderate incontinence? Costs and 2-year outcome. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):193-8. discussion 8. Case-series. [pmid: 12955342].
3285 Otero M, Boulvain M, BianchiDemicheli F, et al. Women's health 18 years after rupture of the anal sphincter during childbirth: II. Urinary incontinence, sexual function, and physical and mental health. American Journal of Obstetrics and Gynecology. May. 2006;194(5):1260-5. Not eligible level of evidence. [pmid: 16579926].
3286 Otero M, Boulvain M, Bianchi-Demicheli F, et al. Women's health 18 years after rupture of the anal sphincter during childbirth: II. Urinary incontinence, sexual function, and physical and mental health. Am J Obstet Gynecol. May. 2006;194(5):1260-5. Not eligible level of evidence. [pmid: 16579926].
3287 Otto IC, Ito K, Ye C, et al. Causes of rectal incontinence after sphincter-preserving operations for rectal cancer. Dis Colon Rectum. Dec. 1996;39(12):1423-7. Case-series. [pmid: 8969670].
3288 Ottoway J. A patient's view. Elder Care. 1999 Dec–2000 Jan;11(9):35. Comment.
3289 Ouslander J, Schnelle J, Simmons S, et al. The dark side of incontinence: nighttime incontinence in nursing home residents. J Am Geriatr Soc. Apr. 1993;41(4):371-6. Not eligible target population. [pmid: 8463522].
3290 Ouslander JG. Intractable incontinence in the elderly. BJU Int. May. 2000;85(Suppl 3):72-8. discussion 81–2. Review. [pmid: 11954202].
3291 Ouslander JG, Ai-Samarrai N, Schnelle JF. Prompted voiding for nighttime incontinence in nursing homes: is it effective?. J Am Geriatr Soc. Jun. 2001;49(6):706-9. Case-series. [pmid: 11454107].
3292 Ouslander JG, Buxton WG, AlSamarrai NR, et al. Nighttime urinary incontinence and sleep disruption among nursing home residents. Journal of the American Geriatrics Society. Apr. 1998;46(4):463-6. Not eligible outcomes. [pmid: 9560069].
3293 Ouslander JG, Buxton WG, Al-Samarrai NR, et al. Nighttime urinary incontinence and sleep disruption among nursing home residents. J Am Geriatr Soc. Apr. 1998;46(4):463-6. Not eligible target population. [pmid: 9560069].
3294 Ouslander JG, Cooper E, Godley D. Estrogen treatment for incontinence in frail older women. J Am Geriatr Soc. Nov. 1999;47(11):1383-4. Letter. [pmid: 10573454].
3295 Ouslander JG, Griffiths P, McConnell E, et al. Functional Incidental Training: applicability and feasibility in the Veterans Affairs nursing home patient population. J Am Med Dir Assoc. Mar–Apr. 2005;6(2):121-7. Not eligible outcomes. [pmid: 15871887].
3296 Ouslander JG, Schapira M, Fingold S, et al. Accuracy of rapid urine screening tests among incontinent nursing home residents with asymptomatic bacteriuria. J Am Geriatr Soc. Jul. 1995;43(7):772-5. Not eligible outcomes. [pmid: 7602029].
3297 Ouslander JG, Schapira M, Schnelle JF. Urine specimen collection from incontinent female nursing home residents. J Am Geriatr Soc. Mar. 1995;43(3):279-81. Not eligible outcomes. [pmid: 7884119].
3298 Ouslander JG, Schapira M, Schnelle JF, et al. Pyuria among chronically incontinent but otherwise asymptomatic nursing home residents. J Am Geriatr Soc. Apr. 1996;44(4):420-3. Not eligible outcomes. [pmid: 8636589].
3299 Ouslander JG, Schapira M, Schnelle JF, et al. Does eradicating bacteriuria affect the severity of chronic urinary incontinence in nursing home residents?. Ann Intern Med. May 15. 1995;122(10):749-54. Not eligible exposure. [pmid: 7717597].
3300 Ouslander JG, Schnelle JF, Uman G, et al. Does oxybutynin add to the effectiveness of prompted voiding for urinary incontinence among nursing home residents? A placebo-controlled trial. J Am Geriatr Soc. Jun. 1995;43(6):610-7. Not eligible exposure. [pmid: 7775717].
3301 Ouslander JG, Simmons S, Schnelle J, et al. Effects of prompted voiding on fecal continence among nursing home residents. J Am Geriatr Soc. Apr. 1996;44(4):424-8. Not eligible target population. [pmid: 8636590].
3302 Ouslander JG, Zarit SH, Orr NK, et al. Incontinence among elderly community-dwelling dementia patients. Characteristics, management, and impact on caregivers. J Am Geriatr Soc. Apr. 1990;38(4):440-5. Not eligible outcomes. [pmid: 2329252].
3303 Owan T, Kohra T, Miyara Y, et al. Urination assessment after the removal of bladder catheter using a novel urination chart. Nurs Health Sci. Sep. 2003;5(3):189-97. Not eligible target population. [pmid: 12877720].
3304 Owen CM, Yell JA. Genital lichen sclerosus associated with incontinence. J Obstet Gynaecol. Mar. 2002;22(2):209-10. Case- Reports. [pmid: 12521711].
3305 Ozel B, Ballard C. Urethral and paraurethral leiomyomas in the female patient. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):93-5. Case Reports. [pmid: 15905997].
3306 Ozel B, Minaglia S, Hurtado E, et al. Treatment of voiding dysfunction after transobturator tape procedure. Urology. Nov. 2004;64(5):1030. Case Reports.
3307 Ozel B, White T, Urwitz-Lane R, et al. The impact of pelvic organ prolapse on sexual function in women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):14-7. Not eligible outcomes. [pmid: 15971004].
3308 Ozkan B, Demirkesen O, Durak H, et al. Which factors predict upper urinary tract deterioration in overactive neurogenic bladder dysfunction?. Urology. Jul. 2005;66(1):99-104. Case-series. [pmid: 15992868].
3309 Ozkan-Seyhan T, Sungur MO, Senturk E, et al. BIS guided sedation with propofol during spinal anaesthesia: influence of anaesthetic level on sedation requirement. Br J Anaesth. May. 2006;96(5):645-9. Case-series. [pmid: 16531442].
3310 Ozturk R, Niazi S, Stessman M, et al. Long-term outcome and objective changes of anorectal function after biofeedback therapy for faecal incontinence. Aliment Pharmacol Ther. Sep 15. 2004;20(6):667-74. Case-series. [pmid: 15352915].
3311 Ozuner G, Strong SA, Fazio VW. Effect of rectosigmoid stump length on restorative proctocolectomy after subtotal colectomy. Dis Colon Rectum. Oct. 1995;38(10):1039-42. Case-series. [pmid: 7555416].
3312 Pagano G, Biondo G, Armaleo F, et al. Complex anal fistula surgery: personal experience. Chir Ital. Jul–Aug. 2004;56(4):523-7. Not eligible exposure. [pmid: 15452991].
3313 Pagliacci MC, Franceschini M, Di Clemente B, et al. A multicentre follow-up of clinical aspects of traumatic spinal cord injury. Spinal Cord. Jun. 2007;45(6):404-10. Not eligible outcomes. [pmid: 17102809].
3314 Paick JS, Kim SW, Ku JH, et al. Preoperative maximal flow rate may be a predictive factor for the outcome of tension-free vaginal tape procedure for stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2004;15(6):413-7. discussion 7. Case-series. [pmid: 15549260].
3315 Paick JS, Ku JH, Shin JW, et al. Complications associated with the tension-free vaginal tape procedure: the Korean experience. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):215-9. Not eligible target population. [pmid: 15875237].
3316 Paick JS, Ku JH, Shin JW, et al. Significance of pad test loss for the evaluation of women with urinary incontinence. Neurourol Urodyn. 2005;24(1):39-43. Not eligible outcomes. [pmid: 15468291].
3317 Paick JS, Ku JH, Shin JW, et al. Shortening of tension-free vaginal tape for the treatment of recurrent incontinence. J Urol. Apr. 2004;171(4):1634. Case Reports. [pmid: 15017244].
3318 Pajoncini C, Costantini E, Guercini F, et al. Clinical and urodynamic features of intrinsic sphincter deficiency. Neurourol Urodyn. 2003;22(4):264-8. Case-series. [pmid: 12808699].
3319 Pajoncini C, Costantini E, Guercini F, et al. Intrinsic sphincter deficiency: do the maximum urethral closure pressure and the Valsalva leak-point pressure identify different pathogenic mechanisms?. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(1):30-5. Case-series. [pmid: 11999202].
3320 Palleschi G, Pastore AL, Stocchi F, et al. Correlation between the Overactive Bladder questionnaire (OAB-q) and urodynamic data of Parkinson disease patients affected by neurogenic detrusor overactivity during antimuscarinic treatment. Clin Neuropharmacol. Jul–Aug. 2006;29(4):220-9. Not eligible outcomes. [pmid: 16855424].
3321 Palma L, Rizzo G, Lio R, et al. Aspecific inflammatory lesion (histiocytosis?) simulating intramedullary astrocytoma. Case report. J Neurosurg Sci. Mar. 1999;43(1):69-72. Case report. [pmid: 10494669].
3322 Palma P, Riccetto C, Herrmann V, et al. Transobturator SAFYRE sling is as effective as the transvaginal procedure. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):487-91. Not eligible target population. [pmid: 15889209].
3323 Palma PC, Dambros M, Riccetto CZ, et al. The Ibero-American experience with a re-adjustable minimally invasive sling. BJU Int. Feb. 2005;95(3):341-5. Not eligible target population. [pmid: 15679790].
3324 Palma PC, Dambros M, Thiel M, et al. Readjustable transobturator sling: a novel sling procedure for male urinary incontinence. Urol Int. 2004;73(4):354-6. Case Reports. [pmid: 15604582].
3325 Palma PC, Riccetto CL, Herrmann V, et al. Repeated lipoinjections for stress urinary incontinence. J Endourol. Feb. 1997;11(1):67-70. Not eligible exposure. [pmid: 9048302].
3326 Palma PC, Thiel M, Riccetto CL, et al. Resiniferatoxin for detrusor instability refractory to anticholinergics. Int Braz J Urol. Jan–Feb. 2004;30(1):53-8. Not eligible target population. [pmid: 15707518].
3327 Palmer MH. Level 1: basic assessment and management of urinary incontinence in nursing homes. Nurse Pract Forum. Sep. 1994;5(3):152-7. No associative hypothesis tested. [pmid: 7950494].
3328 Palmer MH. A health-promotion perspective of urinary continence. Nurs Outlook. Jul–Aug. 1994;42(4):163-9. Review. [pmid: 7984447].
3329 Palmer MH. Nurses' knowledge and beliefs about continence interventions in long-term care. J Adv Nurs. Jun. 1995;21(6):1065-72. Not eligible target population. [pmid: 7665769].
3330 Palmer MH, Baumgarten M, Langenberg P, et al. Risk factors for hospital-acquired incontinence in elderly female hip fracture patients. J Gerontol A Biol Sci Med Sci. Oct. 2002;57(10):M672-7. Not eligible target population. [pmid: 12242323].
3331 Palmer MH, Bennett RG, Marks J, et al. Urinary incontinence: a program that works. J Long Term Care Adm. Summer. 1994;22(2):19-25. No association hypothesis tested.
3332 Palmer MH, Fitzgerald S, Berry SJ, et al. Urinary incontinence in working women: an exploratory study. Women Health. 1999;29(3):67-82. Not eligible level of evidence. [pmid: 10466511].
3333 Palmer MH, McCormick KA, Langford A, et al. Continence outcomes: documentation on medical records in the nursing home environment. J Nurs Care Qual. Apr. 1992;6(3):36-43. [pmid: 1550947].
3334 Palmer MH, Myers AH, Fedenko KM. Urinary continence changes after hip-fracture repair. Clin Nurs Res. Feb. 1997;6(1):8-21. discussion -4. Case-series. [pmid: 9248369].
3335 Palmer MH, Newman DK. Bladder matters: urinary incontinence in nursing homes. Am J Nurs. Nov. 2004;104(11):57-9. Comment. [pmid: 15616452].
3336 Palmer MH, Newman DK. Bladder control educational needs of older adults. J Gerontol Nurs. Jan. 2006;32(1):28-32. Not eligible outcomes. [pmid: 16475462].
3337 Palmieri B, Benuzzi G, Bellini N. The anal bag: a modern approach to fecal incontinence management. Ostomy Wound Manage. Dec. 2005;51(12):44-52. Not eligible exposure.
3338 Palomba S, Russo T, Iuzzolino D, et al. Comparison between two laparoscopic retropubic urethropexy. Minerva Chir. Jun. 2002;57(3):323-9. Not available publication. [pmid: 12029227].
3339 Pang D. Sacral agenesis and caudal spinal cord malformations. Neurosurgery. May. 1993;32(5):755-78. discussion 78–9. Not eligible target population. [pmid: 8492851].
3340 Pang MW, Chan LW, Yip SK. One-year urodynamic outcome and quality of life in patients with concomitant tension-free vaginal tape during pelvic floor reconstruction surgery for genitourinary prolapse and urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):256-60. discussion 9–60. Case-series. [pmid: 14530838].
3341 Pannek J. Vesicostomy in adult meningomyelocele patients. Reappraisal of an old technique. Int Urol Nephrol. 1999;31(5):643-5. Case Reports. [pmid: 10755354].
3342 Pannek J, Haupt G, Sommerfeld HJ, et al. Urodynamic and rectomanometric findings in urinary incontinence. Scand J Urol Nephrol. Dec. 1996;30(6):457-60. Not eligible outcomes. [pmid: 9008025].
3343 Pannek J, Muller M, Haupt G. An unexpected complicationof the remote-controlled intraurethral valve pump for urinary incontinence. Urol Int. 1998;61(4):235-6. Case- Reports. [pmid: 10364756].
3344 Pannek J, Sommerfeld HJ. Ovarian cystoid causing Kock pouch incontinence. Urol Int. 1998;60(1):59-61. Case Reports. [pmid: 9519424].
3345 Panugthong P, Chulyamitporn T, Tanapat Y. Prevalence and risk factors of urinary incontinence in Thai menopausal women at Phramongkutklao Hospital. J Med Assoc Thai. Nov. 2005;88(Suppl 3):S25-30. Not eligible level of evidence. [pmid: 16858941].
3346 Paolucci S, Antonucci G, Grasso MG, et al. The role of unilateral spatial neglect in rehabilitation of right brain-damaged ischemic stroke patients: a matched comparison. Arch Phys Med Rehabil. Jun. 2001;82(6):743-9. Not eligible level of evidence. [pmid: 11387577].
3347 Paolucci S, Matano A, Bragoni M, et al. Rehabilitation of left brain-damaged ischemic stroke patients: the role of comprehension language deficits. A matched comparison. Cerebrovasc Dis. 2005;20(5):400-6. Not eligible level of evidence. [pmid: 16205059].
3348 Papa Petros PE. A cystocele may compensate for latent stress incontinence by stretching the vaginal hammock. Gynecol Obstet Invest. 1998;46(3):206-9. Case-series. [pmid: 9736806].
3349 Papa Petros PE. Cure of urinary and fecal incontinence by pelvic ligament reconstruction suggests a connective tissue etiology for both. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(6):356-60. Case-series. [pmid: 10614969].
3350 Papa Petros PE, Bush MB. A mathematical model for micturition gives new insights into pressure measurement and function. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(2):103-7. Not eligible outcomes. [pmid: 9694140].
3351 Papa Petros PE, Ulmsten U. An analysis of rapid pad testing and the history for the diagnosis of stress incontinence. Acta Obstet Gynecol Scand. Oct. 1992;71(7):529-36. Case-series. [pmid: 1332373].
3352 Papachrysostomou M, Pye SD, Wild SR, et al. Anal endosonography in asymptomatic subjects. Scand J Gastroenterol. Jun. 1993;28(6):551-6. Not eligible outcomes. [pmid: 8322030].
3353 Papachrysostomou M, Pye SD, Wild SR, et al. Significance of the thickness of the anal sphincters with age and its relevance in faecal incontinence. Scand J Gastroenterol. Aug. 1994;29(8):710-4. Not eligible outcomes. [pmid: 7973430].
3354 Papanicolaou S, Hunskaar S, Lose G, et al. Assessment of bothersomeness and impact on quality of life of urinary incontinence in women in France, Germany, Spain and the UK. BJU Int. Oct. 2005;96(6):831-8. Not eligible outcomes. [pmid: 16153212].
3355 Papanicolaou S, Pons ME, Hampel C, et al. Medical resource utilisation and cost of care for women seeking treatment for urinary incontinence in an outpatient setting. Examples from three countries participating in the PURE study. Maturitas. Nov 30. 2005;52(Suppl 2):S35-47. Not eligible exposure. [pmid: 16297577].
3356 Paparella P, Ercoli A, Groutz A, et al. Clinical and urodynamic effects of anterior colporraphy and approximation of pubococcygeus muscles in patients with severe cystocele. Arch Gynecol Obstet. Mar. 2005;271(3):195-9. Case-series. [pmid: 15290166].
3357 Papasakelariou C, Papasakelariou B. Laparoscopic bladder neck suspension. J Am Assoc Gynecol Laparosc. Feb. 1997;4(2):185-9. Case-series. [pmid: 9050726].
3358 Paraiso MF, Walters MD, Rackley RR, et al. Laparoscopic and abdominal sacral colpopexies: a comparative cohort study. Am J Obstet Gynecol. May. 2005;192(5):1752-8. Case-series. [pmid: 15902189].
3359 Parazzini F, Lavezzari M, Arbitani W. Prevalence of overactive bladder and urinary incontinence. J Fam Pract. Dec. 2002;51(12):1072-5. Not eligible level of evidence. [pmid: 12540334].
3360 Pardi DS, Ramnath VR, Loftus EV Jr, et al. Lymphocytic colitis: clinical features, treatment, and outcomes. Am J Gastroenterol. Nov. 2002;97(11):2829-33. Not eligible target population. [pmid: 12425555].
3361 Parellada CM, Miller AS, Williamson ME, et al. Paradoxical high anal resting pressures in men with idiopathic fecal seepage. Dis Colon Rectum. May. 1998;41(5):593-7. Case-series. [pmid: 9593241].
3362 Park JJ, Cintron JR, Orsay CP, et al. Repair of chronic anorectal fistulae using commercial fibrin sealant. Arch Surg. Feb. 2000;135(2):166-9. Not eligible outcomes. [pmid: 10668875].
3363 Park JM, Montie JE. Mechanisms of incontinence and retention after orthotopic neobladder diversion. Urology. Apr. 1998;51(4):601-9. Case-series. [pmid: 9586614].
3364 Park R, Martin S, Goldberg JD, et al. Anastomotic strictures following radical prostatectomy: insights into incidence, effectiveness of intervention, effect on continence, and factors predisposing to occurrence. Urology. Apr. 2001;57(4):742-6. Case-series. [pmid: 11306394].
3365 Park S, Hong B, Lee KS, et al. Risk factors of voiding dysfunction and patient satisfaction after tension-free vaginal tape procedure. J Korean Med Sci. Dec. 2005;20(6):1006-10. Case-series. [pmid: 16361813].
3366 Park SW, Sung DJ, Choi EJ, et al. Comparison of cystographic findings of intrinsic sphincteric deficiency with urethral hypermobility causing urinary incontinence. Urol Int. 2007;78(2):116-20. Case-series. [pmid: 17293649].
3367 Park T, Lee SY. A test of missing completely at random for longitudinal data with missing observations. Stat Med. Aug 30. 1997;16(16):1859-71. No associative hypothesis tested. [pmid: 9280038].
3368 Park T, Lee SY. Simple pattern-mixture models for longitudinal data with missing observations: analysis of urinary incontinence data. Stat Med. Nov 15. 1999;18(21):2933-41. No associative hypothesis tested. [pmid: 10523751].
3369 Parker SC, Spencer MP, Madoff RD, et al. Artificial bowel sphincter: long-term experience at a single institution. Dis Colon Rectum. Jun. 2003;46(6):722-9. Case-series. [pmid: 12794572].
3370 Parkhouse HF, Woodhouse CR. Long-term status of patients with posterior urethral valves. Urol Clin North Am. May. 1990;17(2):373-8. Review. [pmid: 2336745].
3371 Parkkinen A, Karjalainen E, Vartiainen M, et al. Physiotherapy for female stress urinary incontinence: individual therapy at the outpatient clinic versus home-based pelvic floor training: a 5-year follow-up study. Neurourol Urodyn. 2004;23(7):643-8. Case-series. [pmid: 15382186].
3372 Parra RO, Shaker L. Experience with a simplified technique for the treatment of female stress urinary incontinence. Br J Urol. Dec. 1990;66(6):615-7. Case-series. [pmid: 2265334].
3373 Parres JA, Kropp KA. Urodynamic evaluation of the continence mechanism following urethral lengthening—reimplantation and enterocystoplasty. J Urol. Aug. 1991;146(2 Pt 2):535-8. Not eligible target population. [pmid: 1861295].
3374 Partoll LM. Efficacy of tension-free vaginal tape with other pelvic reconstructive surgery. Am J Obstet Gynecol. Jun. 2002;186(6):1292-5. discussion 5–8. Case-series. [pmid: 12066111].
3375 Parys BT, Woolfenden KA, Parsons KF. Bladder dysfunction after simple hysterectomy: urodynamic and neurological evaluation. Eur Urol. 1990;17(2):129-33. Not eligible outcomes. [pmid: 2311638].
3376 Pasaoglu E, Tokoglu F, Boyacigil S, et al. A case of bladder agenesis. Australas Radiol. May. 1997;41(2):201-3. Case Reports. [pmid: 9153827].
3377 Pasceri P. Utilizing a prevention and treatment protocol for skin breakdown secondary to urinary incontinence. Ostomy Wound Manage. Sep–Oct. 1991;36:66-9. Case Reports. [pmid: 1930588].
3378 Patankar SK, Ferrara A, Larach SW, et al. Electromyographic assessment of biofeedback training for fecal incontinence and chronic constipation. Dis Colon Rectum. Aug. 1997;40(8):907-11. Case-series. [pmid: 9269806].
3379 Patankar SK, Ferrara A, Levy JR, et al. Biofeedback in colorectal practice: a multicenter, statewide, three-year experience. Dis Colon Rectum. Jul. 1997;40(7):827-31. Case-series. [pmid: 9221861].
3380 Patel AS, O'Leary ML, Stein RJ, et al. The relationship between overactive bladder and sexual activity in women. Int Braz J Urol. Jan–Feb. 2006;32(1):77-87. Not eligible outcomes. [pmid: 16519834].
3381 Patel H, Peddada AV, Zimmern PE, et al. Risk of incontinence with transurethral resection of the prostate after radiation therapy for prostate cancer. J Surg Oncol. Feb. 1997;64(2):127-9. Case- Reports. [pmid: 9047249].
3382 Patel MD, Coshall C, Rudd AG, et al. Cognitive impairment after stroke: clinical determinants and its associations with long-term stroke outcomes. J Am Geriatr Soc. Apr. 2002;50(4):700-6. Not eligible exposure. [pmid: 11982671].
3383 Paterson J. Stigma associated with postprostatectomy urinary incontinence. J Wound Ostomy Continence Nurs. May. 2000;27(3):168-73. Case-series. [pmid: 10814949].
3384 Patki P, Hamid R, Shah PJ, et al. Long-term efficacy of AMS 800 artificial urinary sphincter in male patients with urodynamic stress incontinence due to spinal cord lesion. Spinal Cord. May. 2006;44(5):297-300. Case-series. [pmid: 16249789].
3385 Patki PS, Hamid R, Arumugam K, et al. Botulinum toxin-type A in the treatment of drug-resistant neurogenic detrusor overactivity secondary to traumatic spinal cord injury. BJU Int. Jul. 2006;98(1):77-82. Case-series. [pmid: 16831148].
3386 Patrick DL, Martin ML, Bushnell DM, et al. Cultural adaptation of a quality-of-life measure for urinary incontinence. Eur Urol. Nov. 1999;36(5):427-35. Not eligible outcomes. [pmid: 10516455].
3387 Patry G, Bolduc S, Martineau G, et al. Colovaginal fistula: an unusual complication of the tension-free vaginal tape procedure. J Urol. Sep. 2004;172(3):972-3. Case Reports. [pmid: 15311013].
3388 Patten J. A case study in evidence-based wound management. Br J Nurs 2000 Jun suppl; 9(12):S38–40, S2, S4 passim. Case Reports
3389 Paty PB, Enker WE, Cohen AM, et al. Long-term functional results of coloanal anastomosis for rectal cancer. Am J Surg. Jan. 1994;167(1):90-4. discussion 4–5. Case-series. [pmid: 8311145].
3390 Pauliina A, Jorma P, Paula I, et al. Intravaginal surface EMG probe design test for urinary incontinence patients. Acupunct Electrother Res. 2002;27(1):37-44. Case-series. [pmid: 12044019].
3391 Pauwels E, De Wachter S, Wyndaele JJ. A normal flow pattern in women does not exclude voiding pathology. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):104-8. discussion 8. Not eligible exposure. [pmid: 15365599].
3392 Peake S, Manderson L. The constraints of a normal life: the management of urinary incontinence by middle aged women. Women Health. 2003;37(3):37-51. Not eligible outcomes. [pmid: 12839306].
3393 Pearl RK, Prasad ML, Nelson RL, et al. Bilateral gluteus maximus transposition for anal incontinence. Dis Colon Rectum. Jun. 1991;34(6):478-81. Case-reports. [pmid: 2036928].
3394 Pearman JW, Bailey M, Riley LP. Bladder instillations of trisdine compared with catheter introducer for reduction of bacteriuria during intermittent catheterisation of patients with acute spinal cord trauma. Br J Urol. May. 1991;67(5):483-90. Not eligible outcomes. [pmid: 1903999].
3395 Pearson BD. Liquidate a myth: reducing liquid intake is not advisable for elderly with urine control problems. Urol Nurs. Sep. 1993;13(3):86-7. Comment. [pmid: 8211250].
3396 Pearson BD, Larson J. Improving elders' continence state. Clin Nurs Res. Nov. 1992;1(4):430-9. Case-series. [pmid: 1483142].
3397 Peeker R, Damber JE, Hjalmas K, et al. The urological fate of young adults with myelomeningocele: a three decade follow-up study. Eur Urol. 1997;32(2):213-7. Case-series. [pmid: 9286656].
3398 Peet SM, Castleden CM, McGrother CW, et al. The management of urinary incontinence in residential and nursing homes for older people. Age Ageing. Mar. 1996;25(2):139-43. Not eligible exposure. [pmid: 8670543].
3399 Peeters ST, Hoogeman MS, Heemsbergen WD, et al. Rectal bleeding, fecal incontinence, and high stool frequency after conformal radiotherapy for prostate cancer: normal tissue complication probability modeling. Int J Radiat Oncol Biol Phys. Sep 1. 2006;66(1):11-9. Secondary data analysis. [pmid: 16757129].
3400 Peguero E, Abou-Khalil B, Fakhoury T, et al. Self-injury and incontinence in psychogenic seizures. Epilepsia. Jun. 1995;36(6):586-91. Not eligible target population. [pmid: 7555972].
3401 Pelissier EP, Blum D, Bachour A, et al. Functional results of coloanal anastomosis with reservoir. Dis Colon Rectum. Sep. 1992;35(9):843-6. Case-series. [pmid: 1511643].
3402 Pelliccioni G, Scarpino O, Piloni V. Motor evoked potentials recorded from external anal sphincter by cortical and lumbo-sacral magnetic stimulation: normative data. J Neurol Sci. Jul. 1997;149(1):69-72. Case-series. [pmid: 9168168].
3403 Pelosi MA 3rd, Pelosi MA. Transvaginal needle suspension with LeFort colpocleisis for stress incontinence and advanced uterovaginal prolapse in a high-risk patient. J Am Assoc Gynecol Laparosc. May. 1998;5(2):207-11. Case report. [pmid: 9564074].
3404 Pelosi MA 3rd, Pelosi MA. Pubic bone suburethral stabilization sling: laparoscopic assessment of a transvaginal operation for the treatment of stress urinary incontinence. J Laparoendosc Adv Surg Tech A. Feb. 1999;9(1):45-50. Case-series. [pmid: 10194692].
3405 Pelsang RE, Rao SS, Welcher K. FECOM: a new artificial stool for evaluating defecation. Am J Gastroenterol. Jan. 1999;94(1):183-6. Not eligible exposure. [pmid: 9934752].
3406 Pelzer AE, Akkad T, Schwentner C, et al. Treatment of adult female epispadias without exstrophy in the presence of rhabdosphincter function. Int J Urol. Mar. 2006;13(3):321-2. Not eligible exposure. [pmid: 16643639].
3407 Pemberton P, Brooks A, Eriksen CM, et al. A comparative study of two types of urinary sheath. Nurs Times. Feb 14–20. 2006;102(7):36-41. Not eligible outcomes.
3408 Pena A, Grasshoff S, Levitt M. Reoperations in anorectal malformations. J Pediatr Surg. Feb. 2007;42(2):318-25. Not eligible target population. [pmid: 17270542].
3409 Penna C, Daude F, Parc R, et al. Previous subtotal colectomy with ileostomy and sigmoidostomy improves the morbidity and early functional results after ileal pouch-anal anastomosis in ulcerative colitis. Dis Colon Rectum. Apr. 1993;36(4):343-8. Not eligible target population. [pmid: 8458259].
3410 Penninckx F. Belgian experience with dynamic graciloplasty for faecal incontinence. Br J Surg. Jul. 2004;91(7):872-8. Case-series. [pmid: 15227694].
3411 Penninckx F, Lestar B, Kerremans R. Manometric evaluation of incontinent patients. Acta Gastroenterol Belg. Jan–Feb. 1995;58(1):51-9. Not eligible outcomes. [pmid: 7604669].
3412 Pereira CE, Lynch JC. Spinal epidural abscess: an analysis of 24 cases. Surg Neurol. 2005;63(Suppl 1):S26-9. Case-series. [pmid: 15629340].
3413 Perez F, Arroyo A, Serrano P, et al. Fistulotomy with primary sphincter reconstruction in the management of complex fistula-in-ano: prospective study of clinical and manometric results. J Am Coll Surg. Jun. 2005;200(6):897-903. Case-series. [pmid: 15922203].
3414 Perez LM, Webster GD. Successful outcome of artificial urinary sphincters in men with post-prostatectomy urinary incontinence despite adverse implantation features. J Urol. Oct. 1992;148(4):1166-70. Case-series. [pmid: 1404630].
3415 Perez M, Lemelle JL, Barthelme H, et al. Bowel management with antegrade colonic enema using a Malone or a Monti conduit—clinical results. Eur J Pediatr Surg. Oct. 2001;11(5):315-8. Not eligible target population. [pmid: 11719869].
3416 Perez MA, Meyerowitz BE, Lieskovsky G, et al. Quality of life and sexuality following radical prostatectomy in patients with prostate cancer who use or do not use erectile aids. Urology. Nov. 1997;50(5):740-6. Case-series. [pmid: 9372885].
3417 Perez N, Garcier JM, Pin-Leveugle J, et al. Dynamic magnetic resonance imaging of the female pelvis: radio-anatomy and pathologic applications. Preliminary results. Surg Radiol Anat. 1999;21(2):133-8. Not eligible outcomes. [pmid: 10399214].
3418 Perfetto EM, Subedi P, Jumadilova Z. Treatment of overactive bladder: a model comparing extended-release formulations of tolterodine and oxybutynin. Am J Manag Care. Jul. 2005;11(4 Suppl):S150-7. Not eligible outcomes. [pmid: 16161388].
3419 Perk H, Oral B, Yesildag A, et al. Magnetic resonance imaging for stress incontinence: evaluation of patients before and after surgical correction. Eur J Radiol. Oct. 2002;44(1):44-7. Case-series. [pmid: 12350411].
3420 Perlmutter AD, Weinstein MD, Reitelman C. Vesical neck reconstruction in patients with epispadias-exstrophy complex. J Urol. Aug. 1991;146(2 Pt 2):613-5. Not eligible target population. [pmid: 1861312].
3421 Perneger TV, Gaspoz JM, Rae AC, et al. Contribution of individual items to the performance of the Norton pressure ulcer prediction scale. J Am Geriatr Soc. Oct. 1998;46(10):1282-6. Not eligible target population. [pmid: 9777913].
3422 Perrotte P, Litwin MS, McGuire EJ, et al. Quality of life after salvage cryotherapy: the impact of treatment parameters. J Urol. Aug. 1999;162(2):398-402. Not eligible level of evidence. [pmid: 10411046].
3423 Perrouin-Verbe B, Labat JJ, Richard I, et al. Clean intermittent catheterisation from the acute period in spinal cord injury patients. Long term evaluation of urethral and genital tolerance. Paraplegia. Nov. 1995;33(11):619-24. Case-series. [pmid: 8584294].
3424 Perry RE, Blatchford GJ, Christensen MA, et al. Manometric diagnosis of anal sphincter injuries. Am J Surg. Jan. 1990;159(1):112-6. discussion 6–7. Question 4. [pmid: 2294787].
3425 Persson G, Barlow L, Karlsson A, et al. Chapter 3. Major health problems. Health in Sweden: The National Public Health Report 2001. Scand J Public Health Suppl. 2001;58:37-102. Secondary data presentation. [pmid: 11708630].
3426 Persson J, Bossmar T, Wolner-Hanssen P. Laparoscopic colposuspension: a short term urodynamic follow-up and a three-year questionnaire-study. Acta Obstet Gynecol Scand. May. 2000;79(5):414-20. Case-series. [pmid: 10830770].
3427 Pescatori M, Anastasio G, Bottini C, et al. New grading and scoring for anal incontinence. Evaluation of 335 patients. Dis Colon Rectum. May. 1992;35(5):482-7. Not eligible target population. [pmid: 1568401].
3428 Pescatori M, Ayabaca S, Caputo D. Can anal manometry predict anal incontinence after fistulectomy in males?. Colorectal Dis. Mar. 2004;6(2):97-102. Case-series. [pmid: 15008906].
3429 Pescatori M, Brusciano L, Binda GA, et al. A novel approach for perirectal tumours: the perianal intersphincteric excision. Int J Colorectal Dis. Jan. 2005;20(1):72-5. Case Reports. [pmid: 15338167].
3430 Pescatori M, Interisano A, Stolfi VM, et al. Delorme's operation and sphincteroplasty for rectal prolapse and fecal incontinence. Int J Colorectal Dis. 1998;13(56):223-7. Case-series. [pmid: 9870165].
3431 Pescatori M, Pavesio R, Anastasio G, et al. Transanal electrostimulation for fecal incontinence: clinical, psychologic, and manometric prospective study. Dis Colon Rectum. Jul. 1991;34(7):540-5. Case-series. [pmid: 2055139].
3432 Peschers UM, DeLancey JO, Schaer GN, et al. Exoanal ultrasound of the anal sphincter: normal anatomy and sphincter defects. Br J Obstet Gynaecol. Sep. 1997;104(9):999-1003. Not eligible outcomes. [pmid: 9307524].
3433 Peschers UM, Fanger G, Schaer GN, et al. Bladder neck mobility in continent nulliparous women. Bjog. Mar. 2001;108(3):320-4. Not eligible exposure. [pmid: 11281475].
3434 Peschers UM, Jundt K, Dimpfl T. Differences between cough and Valsalva leak-point pressure in stress incontinent women. Neurourol Urodyn. 2000;19(6):677-81. Case-series. [pmid: 11071698].
3435 Peters S. Treating fecal incontinence. Restoring self-esteem in your elderly patients. Adv Nurse Pract. Apr. 1998;6(4):63-6. Case report.
3436 Peters WA 3rd, Christenson ML. Fixation of the vaginal apex to the coccygeus fascia during repair of vaginal vault eversion with enterocele. Am J Obstet Gynecol. Jun. 1995;172(6):1894-900. discussion 900–2. Case-series. [pmid: 7778650].
3437 Peterson MD, Matlaga BR, Kim SC, et al. Holmium laser enucleation of the prostate for men with urinary retention. J Urol. Sep. 2005;174(3):998-1001. discussion Case Series. [pmid: 16094022].
3438 Petrelli NJ, Nagel S, Rodriguez-Bigas M, et al. Morbidity and mortality following abdominoperineal resection for rectal adenocarcinoma. Am Surg. Jul. 1993;59(7):400-4. Case-series. [pmid: 8323072].
3439 Petros JA, Catalona WJ. Antegrade approach to radical retropubic prostatectomy in patients with difficult apical dissection. J Urol. May. 1991;145(5):994-7. Case-series. [pmid: 2016817].
3440 Petros P. Changes in bladder neck geometry and closure pressure after midurethral anchoring suggest a musculoelastic mechanism activates closure. Neurourol Urodyn. 2003;22(3):191-7. Not eligible outcomes. [pmid: 12707869].
3441 Petros P, Anderson J. Role of internal anal sphincter damage in the causation of idiopathic faecal incontinence: a prospective study. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):77-8. Case-series. [pmid: 15730372].
3442 Petros PE. The pubourethral ligaments—an anatomical and histological study in the live patient. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(3):154-7. Case-series. [pmid: 9745975].
3443 Petros PE. Symptoms of defective emptying and raised residual urine may arise from ligamentous laxity in the posterior vaginal fornix. Gynecol Obstet Invest. 1998;45(2):105-8. Not eligible outcomes. [pmid: 9517802].
3444 Petros PE, Richardson PA. Midurethral Tissue Fixation System sling — a ‘micromethod’ for cure of stress incontinence — preliminary report. Aust N Z J Obstet Gynaecol. Oct. 2005;45(5):372-5. Case-series. [pmid: 16171470].
3445 Petros PE, Ulmsten U. Tests for ‘detrusor instability’ in women. These mainly measure the urethral resistance created by pelvic floor contraction acting against a premature activation of the micturition reflex. Acta Obstet Gynecol Scand. Nov. 1993;72(8):661-7. Not eligible outcomes. [pmid: 8259755].
3446 Petros PE, Ulmsten U. Natural volume handwashing urethrocystometry: a physiological technique for the objective diagnosis of the unstable detrusor. Gynecol Obstet Invest. 1993;36(1):42-6. Not eligible outcomes. [pmid: 8349178].
3447 Petros PE, Ulmsten U. Urethral pressure increase on effort originates from within the urethra, and continence from musculovaginal closure. Neurourol Urodyn. 1995;14(4):337-46. discussion 46–50. Case-series. [pmid: 7581470].
3448 Petros PE, Ulmsten UI. Non stress non urge female urinary incontinence—diagnosis and cure: a preliminary report. Acta Obstet Gynecol Scand Suppl. 1990;153:69-70. Case-series. [pmid: 2093277].
3449 Petros PE, Ulmsten UI. The tuck procedure: a simplified vaginal repair for treatment of female urinary incontinence. Acta Obstet Gynecol Scand Suppl. 1990;153:41-2. Case-series. [pmid: 2093272].
3450 Petros PE, Ulmsten UI. Cough transmission ratio: an indicator of suburethral vaginal wall tension rather than urethral closure?. Acta Obstet Gynecol Scand Suppl. 1990;153:37-9. Not eligible exposure. [pmid: 2093271].
3451 Petros PE, Ulmsten UI. Pregnancy effects on the intravaginal sling operation. Acta Obstet Gynecol Scand Suppl. 1990;153:77-8. Case-reports. [pmid: 2093281].
3452 Petros PP. The intravaginal slingplasty operation, a minimally invasive technique for cure of urinary incontinence in the female. Aust N Z J Obstet Gynaecol. Nov. 1996;36(4):453-61. Case-series. [pmid: 9006833].
3453 Petros PP, Skilling PM. Pelvic floor rehabilitation in the female according to the integral theory of female urinary incontinence. First report. Eur J Obstet Gynecol Reprod Biol. Feb. 2001;94(2):264-9. Case-series. [pmid: 11165737].
3454 Petrou SP. Does Valsalva leak point pressure predict outcome after the distal urethral polypropylene sling? Role of urodynamics in the sling era. Int Braz J Urol. Jul–Aug. 2004;30(4):355-6. Comment. [pmid: 15679989].
3455 Petrou SP, Broderick GA. Valsalva leak-point pressure changes after successful and failed suburethral sling. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):299-302. Case-series. [pmid: 12355289].
3456 Petrou SP, Brown JA, Blaivas JG. Suprameatal transvaginal urethrolysis. J Urol. Apr. 1999;161(4):1268-71. Case-series. [pmid: 10081883].
3457 Petrou SP, Frank I. Complications and initial continence rates after a repeat pubovaginal sling procedure for recurrent stress urinary incontinence. J Urol. Jun. 2001;165(6 Pt 1):1979-81. Case-series. [pmid: 11371896].
3458 Petrou SP, Kollmorgen TA. Valsalva leak point pressure and bladder volume. Neurourol Urodyn. 1998;17(1):3-7. Case-series. [pmid: 9453686].
3459 Petrou SP, Young PR. Rate of recurrent stress urinary incontinence after retropubic urethrolysis. J Urol. Feb. 2002;167(2 Pt 1):613-5. Case-series. [pmid: 11792929].
3460 Petrovich Z, Lieskovsky G, Langholz B, et al. Radical prostatectomy and postoperative irradiation in patients with pathological stage C (T3) carcinoma of the prostate. Int J Radiat Oncol Biol Phys. Jan 1. 1998;40(1):139-47. Case series. [pmid: 9422570].
3461 Petry H, Berry DL, Spichiger E, et al. Responses and experiences after radical prostatectomy: perceptions of married couples in Switzerland. Int J Nurs Stud. Jul. 2004;41(5):507-13. Not eligible outcomes. [pmid: 15120979].
3462 Pettersen R, Dahl T, Wyller TB. Prediction of long-term functional outcome after stroke rehabilitation. Clin Rehabil. Mar. 2002;16(2):149-59. Not eligible outcomes. [pmid: 11911513].
3463 Pettersen R, Wyller TB. Prognostic significance of micturition disturbances after acute stroke. J Am Geriatr Soc. Dec. 2006;54(12):1878-84. Not eligible level of evidence. [pmid: 17198493].
3464 Peyrat L, Boutin JM, Bruyere F, et al. Intestinal perforation as a complication of tension-free vaginal tape procedure for urinary incontinence. Eur Urol. May. 2001;39(5):603-5. Case Reports. [pmid: 11464045].
3465 Peyromaure M, Dayma T, Zerbib M. Development of a bladder stone following a tension-free vaginal tape intervention. J Urol. Jan. 2004;171(1):337. Case Reports. [pmid: 14665913].
3466 Pezim ME. Successful treatment of horseshoe fistula requires deroofing of deep postanal space. Am J Surg. May. 1994;167(5):513-5. Case-series. [pmid: 8185039].
3467 Pfeifer J. Quality of life after sphincteroplasty. Acta Chir Iugosl. 2004;51(2):73-5. Case-series. [pmid: 15771293].
3468 Pfeifer J, Salanga VD, Agachan F, et al. Variation in pudendal nerve terminal motor latency according to disease. Dis Colon Rectum. Jan. 1997;40(1):79-83. Not eligible outcomes. [pmid: 9102266].
3469 Pfenninger JL, Zainea GG. Common anorectal conditions: Part I. Symptoms and complaints. Am Fam Physician. Jun 15. 2001;63(12):2391-8. Not eligible exposure. [pmid: 11430454].
3470 Pfister C, Cappele O, Dunet F, et al. Assessment of the intrinsic urethral sphincter component function in postprostatectomy urinary incontinence. Neurourol Urodyn. 2002;21(3):194-7. Case-series. [pmid: 11948711].
3471 Pfister SM. Bladder diaries and voiding patterns in older adults. J Gerontol Nurs. Mar. 1999;25(3):36-41. Not eligible outcomes. [pmid: 10362973].
3472 Pfister SM, Dougherty MC. Behavioral management for bladder control: response in selected rural residential care homes. J Community Health Nurs. 1994;11(3):155-64. No associative hypothesis tested. [pmid: 7964934].
3473 Pfisterer MH, Griffiths DJ, Schaefer W, et al. The effect of age on lower urinary tract function: a study in women. J Am Geriatr Soc. Mar. 2006;54(3):405-12. Not eligible outcomes. [pmid: 16551306].
3474 Pfrommer W, Holschneider AM, Loffler N, et al. A new polyurethane anal plug in the treatment of incontinence after anal atresia repair. Eur J Pediatr Surg. Jun. 2000;10(3):186-90. Not eligible target population. [pmid: 10982049].
3475 Phelan MW, Franks M, Somogyi GT, et al. Botulinum toxin urethral sphincter injection to restore bladder emptying in men and women with voiding dysfunction. J Urol. Apr. 2001;165(4):1107-10. Case-series. [pmid: 11257648].
3476 Phelps JY, Lin L, Liu CY. Laparoscopic suburethral sling procedure. J Am Assoc Gynecol Laparosc. Nov. 2003;10(4):496-500. Case-series. [pmid: 14738637].
3477 Philip J, Willmott S, Irwin P. Interstitial cystitis versus detrusor overactivity: a comparative, randomized, controlled study of cystometry using saline and 0.3 M potassium chloride. J Urol. Feb. 2006;175(2):566-70. discussion 70–1. Not eligible exposure. [pmid: 16406997].
3478 Philippe HJ, Perdu M, Dompeyre P, et al. Transvaginal colpo-urethropexy with fibrin sealant: 4 years-follow up in 23 cases. Eur J Obstet Gynecol Reprod Biol. Dec 27. 1996;70(2):157-8. Case Reports. [pmid: 9119096].
3479 Phillips C, Hacking N, Monga A. Super-selective angiographic embolisation of a branch of the anterior pudendal artery for the treatment of intractable post-operative bleeding. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):299-301. Case- Reports. [pmid: 16052291].
3480 Phillips CD, Morris JN, Hawes C, et al. Association of the Resident Assessment Instrument (RAI) with changes in function, cognition, and psychosocial status. J Am Geriatr Soc. Aug. 1997;45(8):986-93. Not eligible outcomes. [pmid: 9256853].
3481 Phillips SF. The diverse spectrum of irritable bowel syndrome. Hosp Pract (Off Ed) 1995 Feb 15; 30(2):69–74, 7; discussion 8. Case- Reports
3482 Phillips TH, Ritchey ML, Dunn CD, et al. Complications of the Heitz-Boyer urinary diversion: case report of late development of malignancy. J Urol. Jul. 1991;146(1):159-61. Case Reports. [pmid: 2056579].
3483 Philp J, Cottenden A, Ledger D. Continence. The reuser's guide. Nurs Times. Oct 28–Nov 3. 1992;88(44):66-72. Not eligible target population. [pmid: 1454573].
3484 Piccini C, Bracco L, Falcini M, et al. Natural history of Alzheimer's disease: prognostic value of plateaux. J Neurol Sci. Aug. 1995;131(2):177-82. Not eligible level of evidence. [pmid: 7595644].
3485 Pieper B, Cleland V. An external urine-collection device for women: a clinical trial. J ET Nurs. Mar–Apr. 1993;20(2):51-5. Not eligible outcomes. [pmid: 8507726].
3486 Pikarsky AJ, Belin B, Efron J, et al. Complications following formalin installation in the treatment of radiation induced proctitis. Int J Colorectal Dis. Apr. 2000;15(2):96-9. Case-series. [pmid: 10855551].
3487 Pike JG, Berardinucci G, Hamburger B, et al. The surgical management of urinary incontinence in myelodysplastic children. J Pediatr Surg. Apr. 1991;26(4):466-70. discussion 70–1. Not eligible target population. [pmid: 2056409].
3488 Piloni V, Fioravanti P, Spazzafumo L, et al. Measurement of the anorectal angle by defecography for the diagnosis of fecal incontinence. Int J Colorectal Dis. Apr. 1999;14(2):131-5. Not eligible outcomes. [pmid: 10367260].
3489 Pils K, Neumann F, Meisner W, et al. Predictors of falls in elderly people during rehabilitation after hip fracture—who is at risk of a second one?. Z Gerontol Geriatr. Feb. 2003;36(1):16-22. Not eligible level of evidence. [pmid: 12616403].
3490 Pinedo G, Vaizey CJ, Nicholls RJ, et al. Results of repeat anal sphincter repair. Br J Surg. Jan. 1999;86(1):66-9. Case-series. [pmid: 10027362].
3491 Pinho M, Ortiz J, Oya M, et al. Total pelvic floor repair for the treatment of neuropathic fecal incontinence. Am J Surg. Mar. 1992;163(3):340-3. Case-series. [pmid: 1539770].
3492 Pinho M, Yoshioka K, Keighley MR. Are pelvic floor movements abnormal in disordered defecation?. Dis Colon Rectum. Dec. 1991;34(12):1117-9. Not eligible outcomes. [pmid: 1959462].
3493 Pinna Pintor M, Zara GP, Falletto E, et al. Pudendal neuropathy in diabetic patients with faecal incontinence. Int J Colorectal Dis. May. 1994;9(2):105-9. Not eligible outcomes. [pmid: 8064189].
3494 Pinta T, Kylanpaa ML, Luukkonen P, et al. Anal incontinence: diagnosis by endoanal US or endovaginal MRI. Eur Radiol. Aug. 2004;14(8):1472-7. Case-series. [pmid: 15064853].
3495 Pinta T, Kylanpaa-Back ML, Salmi T, et al. Delayed sphincter repair for obstetric ruptures: analysis of failure. Colorectal Dis. Jan. 2003;5(1):73-8. Case-series. [pmid: 12780931].
3496 Pinta TM, Kylanpaa ML, Teramo KA, et al. Sphincter rupture and anal incontinence after first vaginal delivery. Acta Obstet Gynecol Scand. Oct. 2004;83(10):917-22. Case-series. [pmid: 15453886].
3497 Pisarska M, Sajdak S. Lower urinary tract function after postoperative radiotherapy in the treatment of cervical cancer. Eur J Gynaecol Oncol. 2003;24(6):490-4. Case-series. [pmid: 14658587].
3498 Pit MJ. Rare complications of tension-free vaginal tape procedure: late intraurethral displacement and early misplacement of tape. J Urol. Feb. 2002;167(2 Pt 1):647. Case Reports. [pmid: 11792940].
3499 Pit MJ, De Ruiter MC, Lycklama ANAA, et al. Anatomy of the arcus tendineus fasciae pelvis in females. Clin Anat. Mar. 2003;16(2):131-7. Not eligible target population. [pmid: 12589667].
3500 Pittman JS, Benson JT, Sumners JE. Physiologic evaluation of the anorectum. A new ultrasound technique. Dis Colon Rectum. Jun. 1990;33(6):476-8. Not eligible outcomes. [pmid: 2190762].
3501 Pla-Marti V, Moro-Valdezate D, Alos-Company R, et al. The effect of surgery on quality of life in patients with faecal incontinence of obstetric origin. Colorectal Dis. Jan. 2007;9(1):90-5. Case-series. [pmid: 17181852].
3502 Plancke HR, Delaere KP, Pons C. Indiana pouch in female patients with spinal cord injury. Spinal Cord. Mar. 1999;37(3):208-10. Case-series. [pmid: 10213332].
3503 Planells Roig M, Sanahuja Santafe A, Garcia Miranda de Larra JL, et al. Prospective analysis of marlex mesh repair for symptomatic rectocele with obstructive defecation. Rev Esp Enferm Dig. Feb. 2002;94(2):67-77. Case-series. [pmid: 12185655].
3504 Poca MA, Sahuquillo J, Busto M, et al. Agreement between CSF flow dynamics in MRI and ICP monitoring in the diagnosis of normal pressure hydrocephalus. Sensitivity and specificity of CSF dynamics to predict outcome. Acta Neurochir Suppl. 2002;81:7-10. Not eligible exposure. [pmid: 12168360].
3505 Podnar S, Mrkaic M, Vodusek DB. Standardization of anal sphincter electromyography: quantification of continuous activity during relaxation. Neurourol Urodyn. 2002;21(6):540-5. Not eligible outcomes. [pmid: 12382244].
3506 Podnar S, Trsinar B, Vodusek DB. Bladder dysfunction in patients with cauda equina lesions. Neurourol Urodyn. 2006;25(1):23-31. Not eligible exposure. [pmid: 16224798].
3507 Poen AC, de Brauw M, Felt-Bersma RJ, et al. Laparoscopic rectopexy for complete rectal prolapse. Clinical outcome and anorectal function tests. Surg Endosc. Sep. 1996;10(9):904-8. Case-series. [pmid: 8703148].
3508 Poen AC, Felt-Bersma RJ, Cuesta MA, et al. Vaginal endosonography of the anal sphincter complex is important in the assessment of faecal incontinence and perianal sepsis. Br J Surg. Mar. 1998;85(3):359-63. Not eligible outcomes. [pmid: 9529493].
3509 Poen AC, Felt-Bersma RJ, Dekker GA, et al. Third degree obstetric perineal tears: risk factors and the preventive role of mediolateral episiotomy. Br J Obstet Gynaecol. May. 1997;104(5):563-6. Not eligible outcomes. [pmid: 9166198].
3510 Pohjasvaara T, Erkinjuntti T, Ylikoski R, et al. Clinical determinants of poststroke dementia. Stroke. Jan. 1998;29(1):75-81. Not eligible outcomes. [pmid: 9445332].
3511 Pohl HG, Bauer SB, Borer JG, et al. The outcome of voiding dysfunction managed with clean intermittent catheterization in neurologically and anatomically normal children. BJU Int. Jun. 2002;89(9):923-7. Not eligible target population. [pmid: 12010241].
3512 Polimeni G, Salvo F, Cutroneo P, et al. Venlafaxine-induced urinary incontinence resolved after switching to sertraline. Clin Neuropharmacol. Sep–Oct. 2005;28(5):247-8. Case- Reports. [pmid: 16239768].
3513 Pollack J, Holm T, Cedermark B, et al. Long-term effect of preoperative radiation therapy on anorectal function. Dis Colon Rectum. Mar. 2006;49(3):345-52. Not eligible level of evidence. [pmid: 16532369].
3514 Pollack J, Nordenstam J, Brismar S, et al. Anal incontinence after vaginal delivery: a five-year prospective cohort study. Obstet Gynecol. Dec. 2004;104(6):1397-402. Not eligible level of evidence. [pmid: 15572505].
3515 Pollak JT, Jenkins P, Kopka SL, et al. Effect of genital prolapse on assessment of bladder neck mobility by the Q-tip test. Obstet Gynecol. Apr. 2003;101(4):662-5. Case-series. [pmid: 12681867].
3516 Polt CA. Taking the pressure off for women with stress incontinence. Nursing. Feb. 2006;36(2):49-51. Case Reports. [pmid: 16462263].
3517 Pomfret I. Continence. Comprehensive care to order. Nurs Times. Apr 10–16. 1996;92(15):62-4. Comment. [pmid: 8710582].
3518 Pontes JE, Montie J, Klein E, et al. Salvage surgery for radiation failure in prostate cancer. Cancer. Feb 1. 1993;71(3 Suppl):976-80. Case-series. [pmid: 8428347].
3519 Ponticelli A, Iacobelli BD, Silveri M, et al. Colorectal dysfunction and faecal incontinence in children with spina bifida. Br J Urol. May. 1998;81(Suppl 3):117-9. Not eligible target population. [pmid: 9634035].
3520 Pool-Goudzwaard AL, Slieker ten Hove MC, Vierhout ME, et al. Relations between pregnancy-related low back pain, pelvic floor activity and pelvic floor dysfunction. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):468-74. Not eligible target population. [pmid: 15803285].
3521 Poore RE, McCullough DL, Jarow JP. Puboprostatic ligament sparing improves urinary continence after radical retropubic prostatectomy. Urology. Jan. 1998;51(1):67-72. Case-series. [pmid: 9457291].
3522 Popat R, Apostolidis A, Kalsi V, et al. A comparison between the response of patients with idiopathic detrusor overactivity and neurogenic detrusor overactivity to the first intradetrusor injection of botulinum-A toxin. J Urol. Sep. 2005;174(3):984-9. Case-series. [pmid: 16094019].
3523 Poppen B, Svenberg T, Bark T, et al. Colectomy-proctomucosectomy with S-pouch: operative procedures, complications, and functional outcome in 69 consecutive patients. Dis Colon Rectum. Jan. 1992;35(1):40-7. Case-series. [pmid: 1733682].
3524 Porru D, Tinelli C, Gerardini M, et al. Evaluation of urinary and general symptoms and correlation with other clinical parameters in interstitial cystitis patients. Neurourol Urodyn. 2005;24(1):69-73. Not eligible level of evidence. [pmid: 15573384].
3525 Porru D, Usai E. Orthotopic ileal bladder substitute after radical cystectomy: urodynamic features. Neurourol Urodyn. 1994;13(3):255-60. Case-series. [pmid: 7920682].
3526 Porru D, Usai E. Standard and extramural ambulatory urodynamic investigation for the diagnosis of detrusor instability-correlated incontinence and micturition disorders. Neurourol Urodyn. 1994;13(3):237-42. Case-series. [pmid: 7920680].
3527 Portier G, Bonhomme N, Platonoff I, et al. Use of Malone antegrade continence enema in patients with perineal colostomy after rectal resection. Dis Colon Rectum. Mar. 2005;48(3):499-503. Not eligible target population. [pmid: 15714242].
3528 Portier G, Iovino F, Lazorthes F. Surgery for rectal prolapse: Orr-Loygue ventral rectopexy with limited dissection prevents postoperative-induced constipation without increasing recurrence. Dis Colon Rectum. Aug. 2006;49(8):1136-40. Case-series. [pmid: 16830210].
3529 Portier G, Platonoff I, Lazorthes F. Long-term functional results after straight or colonic J-pouch coloanal anastomosis. Recent Results Cancer Res. 2005;165:191-5. Case-series. [pmid: 15865033].
3530 Poryazov K. The therapeutic effect of treatment of urinary stress incontinence with estriol. Folia Med (Plovdiv). 1990;32(4):16-9. Case-series. [pmid: 2133559].
3531 Potosky AL, Davis WW, Hoffman RM, et al. Five-year outcomes after prostatectomy or radiotherapy for prostate cancer: the prostate cancer outcomes study. J Natl Cancer Inst. Sep 15. 2004;96(18):1358-67. Not eligible level of evidence. [pmid: 15367568].
3532 Potosky AL, Legler J, Albertsen PC, et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study. J Natl Cancer Inst. Oct 4. 2000;92(19):1582-92. Not eligible level of evidence. [pmid: 11018094].
3533 Potter J. Bowel care in older people. Clin Med. Jan–Feb. 2003;3(1):48-51. Comment. [pmid: 12617414].
3534 Potter J, Peel P, Mian S, et al. National audit of continence care for older people: management of faecal incontinence. Age Ageing. May. 2007;36(3):268-73. Not eligible outcomes. [pmid: 17356002].
3535 Powel LL. Commentary on Abstracts from the literature. Continence. Patient-reported symptoms after primary therapy for early prostate cancer: results of a prospective cohort study original article by Talcott JA, Rieker P, Clark JA, Propert KJ, Weeks JC, Beard CJ et al appears in J CLINICAL ONCOL 1998;16:275–283. Journal of WOCN. Jan. 2000;27(1):14A-5A. Comment.
3536 Powel LL, Clark JA. The value of the marginalia as an adjunct to structured questionnaires: experiences of men after prostate cancer surgery. Qual Life Res. Apr. 2005;14(3):827-35. Case-series. [pmid: 16022075].
3537 Prasher VP, Filer A. Behavioural disturbance in people with Down's syndrome and dementia. J Intellect Disabil Res. Oct. 1995;39(Pt 5):432-6. Not eligible exposure. [pmid: 8555719].
3538 Pregazzi R, Sartore A, Bortoli P, et al. Immediate postpartum perineal examination as a predictor of puerperal pelvic floor dysfunction. Obstet Gynecol. Apr. 2002;99(4):581-4. Not eligible level of evidence. [pmid: 12039115].
3539 Pregazzi R, Sartore A, Bortoli P, et al. Perineal ultrasound evaluation of urethral angle and bladder neck mobility in women with stress urinary incontinence. Bjog. Jul. 2002;109(7):821-7. Not eligible outcomes. [pmid: 12135220].
3540 Preik M, Albrecht D, O'Connell M, et al. Effect of controlled-release delivery on the pharmacokinetics of oxybutynin at different dosages: severity-dependent treatment of the overactive bladder. BJU Int. Oct. 2004;94(6):821-7. Not eligible exposure. [pmid: 15476516].
3541 Preisser JS, Qaqish BF. Robust regression for clustered data with application to binary responses. Biometrics. Jun. 1999;55(2):574-9. Not eligible exposure. [pmid: 11318216].
3542 Presti JC Jr, Schmidt RA, Narayan PA, et al. Pathophysiology of urinary incontinence after radical prostatectomy. J Urol. May. 1990;143(5):975-8. Case-series. [pmid: 2329614].
3543 Prestwood KM, Besdine RW. Geriatric medicine. Jama. Jul 15. 1992;268(3):360-2. Review. [pmid: 1613920].
3544 Prete F, Prete FP, De Luca R, et al. Restorative proctectomy with colon pouch-anal anastomosis by laparoscopic transanal pull-through: an available option for low rectal cancer?. Surg Endosc. Jan. 2007;21(1):91-6. Case-series. [pmid: 17063302].
3545 Pretlove S, Thompson PJ, Toozs-Hobson PM, et al. The first 18 months of a new perineal trauma clinic. J Obstet Gynaecol. Jun. 2004;24(4):399-402. Case Reports. [pmid: 15203580].
3546 Price N, Jackson SR. Clinical audit of the use of tension-free vaginal tape as a surgical treatment for urinary stress incontinence, set against NICE guidelines. J Obstet Gynaecol. Aug. 2004;24(5):534-8. Case-series. [pmid: 15369935].
3547 Pricolo VE. Ileal pouch-anal anastomosis: the “ideal” operation for ulcerative colitis and adenomatous polyposis coli?. R I Med. Nov. 1994;77(11):382-4. Comment. [pmid: 7812055].
3548 Pricolo VE, Potenti FM, Luks FI. Selective preservation of the anal transition zone in ileoanal pouch procedures. Dis Colon Rectum. Aug. 1996;39(8):871-7. Case-series. [pmid: 8756842].
3549 Primus G. One year follow-up on the SPARC sling system for the treatment of female urodynamic stress incontinence. Int J Urol. Nov. 2006;13(11):1410-4. Case-series. [pmid: 17083393].
3550 Primus G, Kramer G. Maximal external electrical stimulation for treatment of neurogenic or non-neurogenic urgency and/or urge incontinence. Neurourol Urodyn. 1996;15(3):187-94. Case-series. [pmid: 8732985].
3551 Probert CS, Jayanthi V, Mayberry JF. Quality of life after colectomy. A comparison of conventional ileostomy and sphincter saving continent procedures. Arq Gastroenterol. Apr–Jun. 1996;33(2):48-51. Question 2. [pmid: 9109968].
3552 Prosser S, Dobbs F. Case-finding incontinence in the over-75s. Br J Gen Pract. Aug. 1997;47(421):498-500. Not eligible outcomes. [pmid: 9302789]. [pmcid: 1313079].
3553 Protogerou V, Moschou M, Antoniou N, et al. Modified S-pouch neobladder vs ileal conduit and a matched control population: a quality-of-life survey. BJU Int. Aug. 2004;94(3):350-4. Not eligible level of evidence. [pmid: 15291866].
3554 Prott G, Hansen R, Badcock C, et al. What is the optimum methodology for the clinical measurement of resting anal sphincter pressure?. Neurogastroenterol Motil. Aug. 2005;17(4):595-9. Case-series. [pmid: 16078949].
3555 Proudfoot LM, Farmer ES, McIntosh JB. Testing incontinence pads using single-case research designs. Br J Nurs 1994 Apr 14–27; 3(7):316, 8–20, 22 passim. Not eligible outcomes
3556 Pruthi RS, Petrus CD, Bundrick WJ. New onset vesicovaginal fistula after transurethral collagen injection in women who underwent cystectomy and orthotopic neobladder creation: presentation and definitive treatment. J Urol. Nov. 2000;164(5):1638-9. Case- Reports. [pmid: 11025723].
3557 Publicover C, Bear M. The effect of bladder training on urinary incontinence in community-dwelling older women. J Wound Ostomy Continence Nurs. Nov. 1997;24(6):319-24. Not eligible target population. [pmid: 9407827].
3558 Pucciani F, Boni D, Perna F, et al. Descending perineum syndrome: are abdominal hysterectomy and bowel habits linked?. Dis Colon Rectum. Nov. 2005;48(11):2094-9. Not eligible target population. [pmid: 16228840].
3559 Pucciani F, Iozzi L, Masi A, et al. Multimodal rehabilitation for faecal incontinence: experience of an Italian centre devoted to faecal disorder rehabilitation. Tech Coloproctol. Oct. 2003;7(3):139-47. discussion 47. Case-series. [pmid: 14628156].
3560 Puet TA, Jackson H, Amy S. Use of pulsed irrigation evacuation in the management of the neuropathic bowel. Spinal Cord. Oct. 1997;35(10):694-9. Case Reports. [pmid: 9347600].
3561 Pugsley H, Barbrook C, Mayne CJ, et al. Morbidity of incontinence surgery in women over 70 years old: a retrospective cohort study. BJOG. Jun. 2005;112(6):786-90. Not eligible outcomes. [pmid: 15924538].
3562 Puppo P, Introini C, Calvi P, et al. Pelvic floor reconstruction before orthotopic bladder replacement after radical cystectomy for bladder cancer. Urology. Jan. 2005;65(1):174. Case Reports.
3563 Pycha A, Klingler CH, Haitel A, et al. Implantable microballoons: an attractive alternative in the management of intrinsic sphincter deficiency. Eur Urol. 1998;33(5):469-75. Case-series. [pmid: 9643666].
3564 Pyne K, Stott M. Continence. Delivering the best service. Nurs Times. Apr 10–16. 1996;92(15):60-2. No associative hypothesis tested. [pmid: 8710581].
3565 Qian LX, Wu HF, Shui YG, et al. Pressure assessment in intercavernous embedding of bulboperineal urethra for treatment of urinary incontinence after prostatic operation. Asian J Androl. Sep. 2001;3(3):235-7. Case-series. [pmid: 11561197].
3566 Quadri G, Magatti F, Belloni C, et al. Transabdominal repair of cystocele by wedge colpectomy during combined abdominal-vaginal surgery. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(5):278-83. Not eligible target population. [pmid: 9557991].
3567 Qualey TL, Jr. An approach to elderly incontinence. Nurs Manage 1995 Apr; 26(4):48Q, S–T. Comment
3568 Quallich SA, Ohl DA. Artificial urinary sphincter case study. Urol Nurs. Aug. 2003;23(4):274-6. Case Reports. [pmid: 14552073].
3569 Quek ML, Ginsberg DA. Long-term urodynamics followup of bladder augmentation for neurogenic bladder. J Urol. Jan. 2003;169(1):195-8. Case-series. [pmid: 12478134].
3570 Quek ML, Ginsberg DA, Wilson S, et al. Pubovaginal slings for stress urinary incontinence following radical cystectomy and orthotopic neobladder reconstruction in women. J Urol. Jul. 2004;172(1):219-21. Case-reports. [pmid: 15201778].
3571 Quinlan DM, Leonard MP, Brendler CB, et al. Use of the Benchekroun hydraulic valve as a catheterizable continence mechanism. J Urol. Jun. 1991;145(6):1151-5. Case-series. [pmid: 2033682].
3572 Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int. May. 2003;91(7):647-52. Not eligible outcomes. [pmid: 12699477].
3573 Quint EH, Smith YR, Bowerman RA, et al. Spasticity of the pelvic floor mimicking an obstructive anomaly. J Pediatr Adolesc Gynecol. Apr. 2003;16(2):83-5. Not eligible exposure. [pmid: 12742141].
3574 Raboy A, Hakim LS, Ferzli G, et al. Extraperitoneal endoscopic vesicourethral suspension. J Laparoendosc Surg. Oct. 1993;3(5):505-8. Comment. [pmid: 8251668].
3575 Rachagan SP, Mathews A. Urinary incontinence caused by prazosin. Singapore Med J. Jun. 1992;33(3):308-9. Case Reports. [pmid: 1631598].
3576 Rackley R, Weiss JP, Rovner ES, et al. Nighttime dosing with tolterodine reduces overactive bladder-related nocturnal micturitions in patients with overactive bladder and nocturia. Urology. Apr. 2006;67(4):731-6. discussion 6. Not eligible exposure. [pmid: 16618562].
3577 Radley SC, Chapple CR, Bryan NP, et al. Effect of methoxamine on maximum urethral pressure in women with genuine stress incontinence: a placebo-controlled, double-blind crossover study. Neurourol Urodyn. 2001;20(1):43-52. Not eligible outcomes. [pmid: 11135381].
3578 Radley SC, Chapple CR, Mitsogiannis IC, et al. Transurethral implantation of macroplastique for the treatment of female stress urinary incontinence secondary to urethral sphincter deficiency. Eur Urol. Apr. 2001;39(4):383-9. Case-series. [pmid: 11306875].
3579 Radomski SB, Caley B, Reiz JL, et al. Preliminary evaluation of a new controlled-release oxybutynin in urinary incontinence. Curr Med Res Opin. 2004;20(2):249-53. Not eligible target population. [pmid: 15006020].
3580 Radomski SB, Herschorn S. Laparoscopic Burch bladder neck suspension: early results. J Urol. Feb. 1996;155(2):515-8. Case-series. [pmid: 8558649].
3581 Radziszewski P, Borkowski A, Torz C, et al. Distribution of collagen type VII in connective tissues of postmenopausal stress-incontinent women. Gynecol Endocrinol. Mar. 2005;20(3):121-6. Not eligible outcomes. [pmid: 16019349].
3582 Rafii A, Darai E, Haab F, et al. Body mass index and outcome of tension-free vaginal tape. Eur Urol. Mar. 2003;43(3):288-92. Case-series. [pmid: 12600433].
3583 Rafii A, Jacob D, Deval B. Obturator abscess after transobturator tape for stress urinary incontinence. Obstet Gynecol. Sep. 2006;108(3 Pt 2):720-3. Case Reports. [pmid: 17018477].
3584 Rafique M, Arif MH. Management of iatrogenic ureteric injuries associated with gynecological surgery. Int Urol Nephrol. 2002;34(1):31-5. Case-series. [pmid: 12549636].
3585 Raghavan P, Raza WA, Ahmed YS, et al. Prevalence of pressure sores in a community sample of spinal injury patients. Clin Rehabil. Dec. 2003;17(8):879-84. Not eligible outcomes. [pmid: 14682560].
3586 Rahman NU, Minor TX, Deng D, et al. Combined external urethral bulking and artificial urinary sphincter for urethral atrophy and stress urinary incontinence. BJU Int. Apr. 2005;95(6):824-6. Case-series. [pmid: 15794791].
3587 Rahn DD, Marinis SI, Schaffer JI, et al. Anatomical path of the tension-free vaginal tape: reassessing current teachings. Am J Obstet Gynecol. Dec. 2006;195(6):1809-13. Not eligible target population. [pmid: 17132484].
3588 Rainey JB, Donaldson DR, Thomson JP. Postanal repair: which patients derive most benefit?. J R Coll Surg Edinb. Apr. 1990;35(2):101-5. Case-series. [pmid: 2355371].
3589 Rait G, Fletcher A, Smeeth L, et al. Prevalence of cognitive impairment: results from the MRC trial of assessment and management of older people in the community. Age Ageing. May. 2005;34(3):242-8. Not eligible level of evidence. [pmid: 15863409].
3590 Raiwet C, Phillips D. A regional approach to continence management. Can Nurse. Apr. 2001;97(4):16-20. Comment. [pmid: 11865514].
3591 Raj GV, Peterson AC, Toh KL, et al. Outcomes following revisions and secondary implantation of the artificial urinary sphincter. J Urol. Apr. 2005;173(4):1242-5. Case-series. [pmid: 15758761].
3592 Raj GV, Peterson AC, Webster GD. Outcomes following erosions of the artificial urinary sphincter. J Urol. Jun. 2006;175(6):2186-90. discussion 90. Case-series. [pmid: 16697836].
3593 Rajkumar GN, Small DR, Mustafa AW, et al. A prospective study to evaluate the safety, tolerability, efficacy and durability of response of intravesical injection of botulinum toxin type A into detrusor muscle in patients with refractory idiopathic detrusor overactivity. BJU Int. Oct. 2005;96(6):848-52. Not eligible target population. [pmid: 16153215].
3594 Rajpurkar AD, Onur R, Singla A. Patient satisfaction and clinical efficacy of the new perineal bone-anchored male sling. Eur Urol. Feb. 2005;47(2):237-42. discussion 42. Case-series. [pmid: 15661420].
3595 Ramakrishnan V, Southern S, Hart NB, et al. Endoscopically assisted gracilis harvest for use as a free and pedicled flap. Br J Plast Surg. Dec. 1998;51(8):580-3. Case Reports. [pmid: 10209458].
3596 Ramanujam PS, Venkatesh KS, Fietz MJ. Perineal excision of rectal procidentia in elderly high-risk patients. A ten-year experience. Dis Colon Rectum. Oct. 1994;37(10):1027-30. Case-series. [pmid: 7924710].
3597 Ramchandani P, Banner MP, Berlin JW, et al. Vesicourethral anastomotic strictures after radical prostatectomy: efficacy of transurethral balloon dilation. Radiology. Nov. 1994;193(2):345-9. Case-series. [pmid: 7972741].
3598 Ramirez JM, Aguilella V, Martinez M, et al. The utility of endovaginal sonography in the evaluation of fecal incontinence. Rev Esp Enferm Dig. May. 2005;97(5):317-22. Case-series. [pmid: 16004523].
3599 Ramon J, Leandri P, Rossignol G, et al. Preservation of urinary continence and potency after cystoprostatectomy. Prog Clin Biol Res. 1992;378:125-32. Case series. [pmid: 1301573].
3600 Ramon J, Mekras JA, Webster GD. The outcome of transvaginal cystourethropexy in patients with anatomical stress urinary incontinence and outlet weakness. J Urol. Jul. 1990;144(1):106-8. discussion 8–9. Case-series. [pmid: 2359155].
3601 Ramon J, Rossignol G, Leandri P, et al. Morbidity of radical retropubic prostatectomy following previous prostate resection. J Surg Oncol. Jan. 1994;55(1):14-9. Not eligible level of evidence. [pmid: 8289445].
3602 Ramoso-Jalbuena J. Climacteric Filipino women: a preliminary survey in the Philippines. Maturitas. Oct. 1994;19(3):183-90. Not eligible level of evidence. [pmid: 7799824].
3603 Ramsay IN, Ali HM, Hunter M, et al. A prospective, randomized controlled trial of inpatient versus outpatient continence programs in the treatment of urinary incontinence in the female. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(5):260-3. Not eligible exposure. [pmid: 9127183].
3604 Rannestad T, Eikeland OJ, Helland H, et al. Are the physiologically and psychosocially based symptoms in women suffering from gynecological disorders alleviated by means of hysterectomy?. J Womens Health Gend Based Med. Jul–Aug. 2001;10(6):579-87. Not eligible level of evidence. [pmid: 11559455].
3605 Rantz MJ. Examining MDS (Minimum Data Set) resident assessments for the impact on public policy. J Long Term Care Adm. Fall–Winter. 1995;23(3):18-21. Not eligible exposure. [pmid: 10156663].
3606 Rao GN, Drew PJ, Lee PW, et al. Anterior resection syndrome is secondary to sympathetic denervation. Int J Colorectal Dis. 1996;11(5):250-8. Case-series. [pmid: 8951517].
3607 Rao J, Koay SK, Lau WK, et al. Patient-reported urinary continence (third-party interview): results of post-radical retropubic prostatectomy in Singaporeans. Asian J Surg. Jul. 2005;28(3):207-10. Case-series. [pmid: 16024318].
3608 Rao KA, Yazaki E, Evans DF, et al. Objective evaluation of small bowel and colonic transit time using pH telemetry in athletes with gastrointestinal symptoms. Br J Sports Med. Aug. 2004;38(4):482-7. Case-series. [pmid: 15273191]. [pmcid: 1724875].
3609 Rao SS, Ozturk R, Stessman M. Investigation of the pathophysiology of fecal seepage. Am J Gastroenterol. Nov. 2004;99(11):2204-9. Not eligible outcomes. [pmid: 15555003].
3610 Rao SS, Patel RS. How useful are manometric tests of anorectal function in the management of defecation disorders?. Am J Gastroenterol. Mar. 1997;92(3):469-75. Not eligible outcomes. [pmid: 9068472].
3611 Rao SS, Welcher KD, Happel J. Can biofeedback therapy improve anorectal function in fecal incontinence?. Am J Gastroenterol. Nov. 1996;91(11):2360-6. Case-series. [pmid: 8931418].
3612 Rapp DE, Lucioni A, Katz EE, et al. Use of botulinum-A toxin for the treatment of refractory overactive bladder symptoms: an initial experience. Urology. Jun. 2004;63(6):1071-5. Not eligible target population. [pmid: 15183952].
3613 Rapp DE, O'Connor RC, Katz EE, et al. Neobladder-vaginal fistula after cystectomy and orthotopic neobladder construction. BJU Int. Nov. 2004;94(7):1092-5. discussion 5. Case-series. [pmid: 15541134].
3614 Rardin CR, Kohli N, Rosenblatt PL, et al. Tension-free vaginal tape: outcomes among women with primary versus recurrent stress urinary incontinence. Obstet Gynecol. Nov. 2002;100(5 Pt 1):893-7. Case-series. [pmid: 12423849].
3615 Rasmussen A, Mouritsen L, Dalgaard A, et al. Twenty-four hour pad weighing test: reproducibility and dependency of activity level and fluid intake. Neurourol Urodyn. 1994;13(3):261-5. Case-series. [pmid: 7920683].
3616 Rasmussen KL, Krue S, Johansson LE, et al. Obesity as a predictor of postpartum urinary symptoms. Acta Obstet Gynecol Scand. Apr. 1997;76(4):359-62. Not eligible level of evidence. [pmid: 9174432].
3617 Rasmussen O, Christensen B, Sorensen M, et al. Rectal compliance in the assessment of patients with fecal incontinence. Dis Colon Rectum. Aug. 1990;33(8):650-3. Not eligible outcomes. [pmid: 2376221].
3618 Rasmussen OO, Buntzen S, Sorensen M, et al. Sacral nerve stimulation in fecal incontinence. Dis Colon Rectum. Jul. 2004;47(7):1158-62. discussion 62–3. Case-series. [pmid: 15216409].
3619 Rasmussen OO, Christiansen J, Tetzschner T, et al. Pudendal nerve function in idiopathic fecal incontinence. Dis Colon Rectum. May. 2000;43(5):633-6. discussion 6–7. Not eligible target population. [pmid: 10826423].
3620 Rasmussen OO, Colstrup H, Lose G, et al. A technique for the dynamic assessment of anal sphincter function. Int J Colorectal Dis. Aug. 1990;5(3):135-41. Not eligible exposure. [pmid: 2212842].
3621 Rasmussen OO, Petersen IK, Christiansen J. Anorectal function following low anterior resection. Colorectal Dis. May. 2003;5(3):258-61. Case-series. [pmid: 12780889].
3622 Rasmussen OO, Puggaard L, Christiansen J. Anal sphincter repair in patients with obstetric trauma: age affects outcome. Dis Colon Rectum. Feb. 1999;42(2):193-5. Case-series. [pmid: 10211495].
3623 Rasmussen OO, Ronholt C, Alstrup N, et al. Anorectal pressure gradient and rectal compliance in fecal incontinence. Int J Colorectal Dis. 1998;13(4):157-9. Not eligible outcomes. [pmid: 9810518].
3624 Rasmussen OO, Sorensen M, Tetzschner T, et al. Anorectal pressure gradient in patients with anal incontinence. Dis Colon Rectum. Jan. 1992;35(1):8-11. Not eligible level of evidence. [pmid: 1733690].
3625 Rasmussen OO, Sorensen M, Tetzschner T, et al. Dynamic anal manometry: physiological variations and pathophysiological findings in fecal incontinence. Gastroenterology. Jul. 1992;103(1):103-13. Question 4. [pmid: 1612318].
3626 Ratto C, Grillo E, Parello A, et al. Endoanal ultrasound-guided surgery for anal fistula. Endoscopy. Aug. 2005;37(8):722-8. Case-series. [pmid: 16032490].
3627 Ratto C, Grillo E, Parello A, et al. Sacral neuromodulation in treatment of fecal incontinence following anterior resection and chemoradiation for rectal cancer. Dis Colon Rectum. May. 2005;48(5):1027-36. Case-series. [pmid: 15785890].
3628 Ratto C, Morelli U, Paparo S, et al. Minimally invasive sacral neuromodulation implant technique: modifications to the conventional procedure. Dis Colon Rectum. Mar. 2003;46(3):414-7. Case-series. [pmid: 12626921].
3629 Ravetz RS. Psychiatric disorders associated with Alzheimer's disease. J Am Osteopath Assoc. Sep. 1999;99(9 Suppl):S13-6. No associative hypothesis tested.
3630 Ravid A, Richard CS, Spencer LM, et al. Pregnancy, delivery, and pouch function after ileal pouch-anal anastomosis for ulcerative colitis. Dis Colon Rectum. Oct. 2002;45(10):1283-8. Case-series. [pmid: 12394423].
3631 Rayome RG, Johnson V, Gray M. Stress urinary incontinence after radical prostatectomy. J Wound Ostomy Continence Nurs. Nov. 1994;21(6):264-9. Case Reports. [pmid: 7704135].
3632 Rayome RG, King C, King T. Patient with nocturnal enuresis and stress incontinence after previous hysterectomy and radiation therapy for cervical cancer. J Wound Ostomy Continence Nurs. Jan. 1995;22(1):64-7. Case- Reports. [pmid: 7704146].
3633 Raz R, Gennesin Y, Wasser J, et al. Recurrent urinary tract infections in postmenopausal women. Clin Infect Dis. Jan. 2000;30(1):152-6. Not eligible outcomes. [pmid: 10619744].
3634 Raz S. Vaginal surgery for stress incontinence. J Am Geriatr Soc. Mar. 1990;38(3):345-7. Comment. [pmid: 2313012].
3635 Raz S, Little NA, Juma S, et al. Repair of severe anterior vaginal wall prolapse (grade IV cystourethrocele). J Urol. Oct. 1991;146(4):988-92. Case-series. [pmid: 1895456].
3636 Raz S, Nitti VW, Bregg KJ. Transvaginal repair of enterocele. J Urol. Apr. 1993;149(4):724-30. Case-series. [pmid: 8455231].
3637 Raz S, Stothers L, Young GP, et al. Vaginal wall sling for anatomical incontinence and intrinsic sphincter dysfunction: efficacy and outcome analysis. J Urol. Jul. 1996;156(1):166-70. Case-series. [pmid: 8648784].
3638 Razdan S, Vlachiotis JD, Edelstein RA, et al. Schistosomal myelopathy as a cause of neurogenic bladder dysfunction. Urology. May. 1997;49(5):777-80. Case Reports. [pmid: 9145991].
3639 Read NW, Sun WM. Reflex anal dilatation: effect of parting the buttocks on anal function in normal subjects and patients with anorectal and spinal disease. Gut. Jun. 1991;32(6):670-3. Not eligible exposure. [pmid: 2060876]. [pmcid: 1378886].
3640 Rechberger T, Donica H, Baranowski W, et al. Female urinary stress incontinence in terms of connective tissue biochemistry. Eur J Obstet Gynecol Reprod Biol. May. 1993;49(3):187-91. Not eligible outcomes. [pmid: 8405633].
3641 Rechberger T, Postawski K, Jakowicki JA, et al. Role of fascial collagen in stress urinary incontinence. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1511-4. Not eligible outcomes. [pmid: 9855589].
3642 Reddy AP, DeLancey JO, Zwica LM, et al. On-screen vector-based ultrasound assessment of vesical neck movement. Am J Obstet Gynecol. Jul. 2001;185(1):65-70. Not eligible outcomes. [pmid: 11483906].
3643 Reddy SM, Ruby J, Wallace M, et al. Patient self-assessment of complications and quality of life after conformal neutron and photon irradiation for localized prostate cancer. Radiat Oncol Investig. 1997;5(5):252-6. Case-series.
3644 Reed RL, Hepburn K, Adelson R, et al. Low serum albumin levels, confusion, and fecal incontinence: are these risk factors for pressure ulcers in mobility-impaired hospitalized adults?. Gerontology. Jul–Aug. 2003;49(4):255-9. Not eligible outcomes. [pmid: 12792162].
3645 Regensberg D. Objective social continence: understanding continence. Nurs RSA. May. 1994;9(5):23-6. Comment. [pmid: 8058097].
3646 Reichelt O, Weirich T, Wunderlich H, et al. Pubovaginal cutaneous fascial sling procedure for stress urinary incontinence: 10 years' experience. Urol Int. 2004;72(4):318-23. discussion 23–4. Case-series. [pmid: 15153730].
3647 Reid SV, Parys BT. Long-term 5-year followup of the results of the vesica procedure. J Urol. Apr. 2005;173(4):1234-6. Case-series. [pmid: 15758759].
3648 Reilly WT, Talley NJ, Pemberton JH, et al. Validation of a questionnaire to assess fecal incontinence and associated risk factors: Fecal Incontinence Questionnaire. Dis Colon Rectum. Feb. 2000;43(2):146-53. discussion 53–4. Not eligible outcomes. [pmid: 10696886].
3649 Reis F, Netto NR Jr, Reinato JA, et al. The impact of prostatectomy and brachytherapy in patients with localized prostate cancer. Int Urol Nephrol. 2004;36(2):187-90. Case series. [pmid: 15368690].
3650 Reisinger E, Stummvoll W. Visualization of the endopelvic fascia by transrectal three-dimensional ultrasound. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2006;17(2):165-9. Not eligible outcomes. [pmid: 15830116].
3651 Reissman P, Agachan F, Wexner SD. Outcome of laparoscopic colorectal surgery in older patients. Am Surg. Dec. 1996;62(12):1060-3. Case-series. [pmid: 8955249].
3652 Reitz A, Schmid DM, Curt A, et al. Afferent fibers of the pudendal nerve modulate sympathetic neurons controlling the bladder neck. Neurourol Urodyn. 2003;22(6):597-601. Case-series. [pmid: 12951671].
3653 Remsburg RE, Palmer MH, Langford AM, et al. Staff compliance with and ratings of effectiveness of a prompted voiding program in a long-term care facility. J Wound Ostomy Continence Nurs. Sep. 1999;26(5):261-9. Not eligible outcomes. [pmid: 10795210].
3654 Remzi FH, Gorgun E, Bast J, et al. Vaginal delivery after ileal pouch-anal anastomosis: a word of caution. Dis Colon Rectum. Sep. 2005;48(9):1691-9. Case-series. [pmid: 16142432].
3655 Renner K, Rosen HR, Novi G, et al. Quality of life after surgery for rectal cancer: do we still need a permanent colostomy?. Dis Colon Rectum. Sep. 1999;42(9):1160-7. Case-series. [pmid: 10496556].
3656 Renschler TD, Middleton RG. 30 years of experience with York-Mason repair of recto-urinary fistulas. J Urol. Oct. 2003;170(4 Pt 1):1222-5. discussion 5. Case-series. [pmid: 14501729].
3657 Rentsch M, Paetzel C, Lenhart M, et al. Dynamic magnetic resonance imaging defecography: a diagnostic alternative in the assessment of pelvic floor disorders in proctology. Dis Colon Rectum. Jul. 2001;44(7):999-1007. Not eligible outcomes. [pmid: 11496081].
3658 Renzi A, Brusciano L, Pescatori M, et al. Pneumatic balloon dilatation for chronic anal fissure: a prospective, clinical, endosonographic, and manometric study. Dis Colon Rectum. Jan. 2005;48(1):121-6. Not eligible target population. [pmid: 15690668].
3659 Resnick B. A bladder scan trial in geriatric rehabilitation. Rehabil Nurs 1995 Jul–Aug; 20(4):194–6, 203. Not eligible outcomes
3660 Resnick N, Fenner D. Toward optimal health: the experts respond to urinary incontinence. J Womens Health. May. 1998;7(4):419-24. Interview. [pmid: 9611698].
3661 Resnick NM. Noninvasive diagnosis of the patient with complex incontinence. Gerontology. 1990;36(Suppl 2):8-18. [pmid: 2227475].
3662 Resnick NM. Urinary incontinence in older adults. Hosp Pract (Off Ed) 1992 Oct 15; 27(10):139–42, 47, 50 passim. Comment
3663 Resnick NM. An 89-year-old woman with urinary incontinence. Jama. Dec 11. 1996;276(22):1832-40. Case- Reports. [pmid: 8946905].
3664 Rett MT, Simoes JA, Herrmann V, et al. Management of stress urinary incontinence with surface electromyography-assisted biofeedback in women of reproductive age. Phys Ther. Feb. 2007;87(2):136-42. Case-series. [pmid: 17213411].
3665 Retzky SS, Rogers RM Jr. Urinary incontinence in women. Clin Symp. 1995;47(3):2-32. Review. [pmid: 8919851].
3666 Reuben DB, Frank JC, Hirsch SH, et al. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. Mar. 1999;47(3):269-76. Not eligible outcomes. [pmid: 10078887].
3667 Reuben DB, Maly RC, Hirsch SH, et al. Physician implementation of and patient adherence to recommendations from comprehensive geriatric assessment. Am J Med. Apr. 1996;100(4):444-51. Not eligible outcomes. [pmid: 8610732].
3668 Reuben DB, Roth C, Kamberg C, et al. Restructuring primary care practices to manage geriatric syndromes: the ACOVE-2 intervention. J Am Geriatr Soc. Dec. 2003;51(12):1787-93. Not eligible outcomes. [pmid: 14687359].
3669 Rex DK, Lappas JC. Combined anorectal manometry and defecography in 50 consecutive adults with fecal incontinence. Dis Colon Rectum. Nov. 1992;35(11):1040-5. Case-series. [pmid: 1425047].
3670 Rex DK, Lappas JC, Goulet RC, et al. Selection of constipated patients as subtotal colectomy candidates. J Clin Gastroenterol. Oct. 1992;15(3):212-7. Not eligible exposure. [pmid: 1479164].
3671 Reyes-Ortiz CA, Al Snih S, Markides KS. Falls among elderly persons in Latin America and the Caribbean and among elderly Mexican-Americans. Rev Panam Salud Publica. May–Jun. 2005;17(56):362-9. Not eligible outcomes. [pmid: 16053646].
3672 Reymert J, Hunskaar S. Why do only a minority of perimenopausal women with urinary incontinence consult a doctor?. Scand J Prim Health Care. Sep. 1994;12(3):180-3. Not eligible outcomes. [pmid: 7997696].
3673 Rezapour M, Falconer C, Ulmsten U. Tension-Free vaginal tape (TVT) in stress incontinent women with intrinsic sphincter deficiency (ISD)—a long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S12-4. Case-series. [pmid: 11450973].
3674 Rezapour M, Ulmsten U. Tension-Free vaginal tape (TVT) in women with recurrent stress urinary incontinence—a long-term follow up. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S9-11. Case-series. [pmid: 11450980].
3675 Rezapour M, Ulmsten U. Tension-Free vaginal tape (TVT) in women with mixed urinary incontinence—a long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S15-8. Case-series. [pmid: 11450974].
3676 Reznicek SB. Common urologic problems in the elderly. Prostate cancer, outlet obstruction, and incontinence require special management. Postgrad Med 2000 Jan; 107(1):163–4, 7–70, 77–8. Review
3677 Rhee EY. Technique for concomitant implantation of the penile prosthesis with the male sling. J Urol. Mar. 2005;173(3):925-7. Case-series. [pmid: 15711332].
3678 Rhodes P. The sound of silence. Health Serv J. Oct 21. 1993;103(5375):28-9. Comment. [pmid: 10129741].
3679 Rhodes P, Parker G. Continence. Profile of an adviser. Nurs Times. Jan 26–Feb 1. 1994;90(4):75-8. Comment. [pmid: 8108266].
3680 Ribera MC, Pascual R, Orozco D, et al. Incidence and risk factors associated with urinary tract infection in diabetic patients with and without asymptomatic bacteriuria. Eur J Clin Microbiol Infect Dis. Jun. 2006;25(6):389-93. Not eligible outcomes. [pmid: 16767487].
3681 Ricciardi R, Mellgren AF, Madoff RD, et al. The utility of pudendal nerve terminal motor latencies in idiopathic incontinence. Dis Colon Rectum. Jun. 2006;49(6):852-7. Not eligible outcomes. [pmid: 16598403].
3682 Richards KC, Beck C, Shue VM, et al. Demographic and sleep characteristics in cognitively impaired nursing home residents with and without severe sleep/wake pattern inefficiency. Issues Ment Health Nurs. Aug–Sep. 2005;26(7):751-69. Not eligible exposure. [pmid: 16126650].
3683 Richardson DA, Ramahi A. Reproducibility of pressure transmission ratios in stress incontinent women. Neurourol Urodyn. 1993;12(2):123-30. Not eligible outcomes. [pmid: 7920668].
3684 Richardson TD, Kennelly MJ, Faerber GJ. Endoscopic injection of glutaraldehyde cross-linked collagen for the treatment of intrinsic sphincter deficiency in women. Urology. Sep. 1995;46(3):378-81. Not eligible target population. [pmid: 7660513].
3685 Richman M, McLaughlin S, Maygarden S, et al. Initial incision of lateral pelvic fascia and early ligation of vascular pedicles during radical prostatectomy: potential to reduce positive margin rates. BJU Int. Jan. 2005;95(1):40-5. Case-series. [pmid: 15638893].
3686 Richmond D. The incontinent woman: 1. Br J Hosp Med. Oct 6–19. 1993;50(7):418-23. Comment. [pmid: 8261290].
3687 Richter HE, Burgio KL, Brubaker L, et al. Factors associated with incontinence frequency in a surgical cohort of stress incontinent women. Am J Obstet Gynecol. Dec. 2005;193(6):2088-93. Not eligible target population. [pmid: 16325621].
3688 Richter HE, Burgio KL, Holley RL, et al. Cadaveric fascia lata sling for stress urinary incontinence: a prospective quality-of-life analysis. Am J Obstet Gynecol. Dec. 2003;189(6):1590-5. discussion 5–6. Not eligible outcomes. [pmid: 14710075].
3689 Richter HE, Fielding JR, Bradley CS, et al. Endoanal ultrasound findings and fecal incontinence symptoms in women with and without recognized anal sphincter tears. Obstet Gynecol. Dec. 2006;108(6):1394-401. Not eligible level of evidence. [pmid: 17138772].
3690 Richter HE, Norman AM, Burgio KL, et al. Tension-free vaginal tape: a prospective subjective and objective outcome analysis. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):109-13. Case-series. [pmid: 15789144].
3691 Richter HE, Varner RE, Sanders E, et al. Effects of pubovaginal sling procedure on patients with urethral hypermobility and intrinsic sphincteric deficiency: would they do it again?. Am J Obstet Gynecol. Jan. 2001;184(2):14-9. Case-series. [pmid: 11174473].
3692 Riedler I, Primus G, Trummer H, et al. Fournier's gangrene after tension-free vaginal tape (TVT) procedure. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):145-6. Case- Reports. [pmid: 15014944].
3693 Riedy LW, Chintam R, Walter JS. Use of a neuromuscular stimulator to increase anal sphincter pressure. Spinal Cord. Dec. 2000;38(12):724-7. Case-series. [pmid: 11175371].
3694 Rieger N, Schloithe A, Saccone G, et al. A prospective study of anal sphincter injury due to childbirth. Scand J Gastroenterol. Sep. 1998;33(9):950-5. Not eligible outcomes. [pmid: 9759951].
3695 Rieger NA, Downey PR, Wattchow DA. Short communication: endoanal ultrasound during contraction of the anal sphincter—improved definition and diagnostic accuracy. Br J Radiol. Jul. 1996;69(823):665-7. Not eligible outcomes. [pmid: 8696705].
3696 Rieger NA, Sarre RG, Saccone GT, et al. Correlation of pudendal nerve terminal motor latency with the results of anal manometry. Int J Colorectal Dis. 1997;12(5):303-7. Not eligible outcomes. [pmid: 9401847].
3697 Rieger NA, Sweeney JL, Hoffmann DC, et al. Investigation of fecal incontinence with endoanal ultrasound. Dis Colon Rectum. Aug. 1996;39(8):860-4. Case-series. [pmid: 8756840].
3698 Rieger NA, Wattchow DA, Sarre RG, et al. Prospective trial of pelvic floor retraining in patients with fecal incontinence. Dis Colon Rectum. Jul. 1997;40(7):821-6. Not eligible target population. [pmid: 9221860].
3699 Rigby D, Whelan L. Parkinson's disease—continence management. Nurs Times. Jul 26–Aug 1. 2001;97(30):65-6. Not eligible exposure. [pmid: 11957964].
3700 Rigby M. Call for early diagnosis in continence care. Elder Care. Feb–Mar. 1996;8(1):33. [pmid: 8696280].
3701 Riley DE, Lang AE. The spectrum of levodopa-related fluctuations in Parkinson's disease. Neurology. Aug. 1993;43(8):1459-64. Case- Reports. [pmid: 8350996].
3702 Ring H, Tshuva M, Ronen R, et al. Quality of care on a stroke rehabilitation ward: the use of urinary incontinence as tracer. Int J Rehabil Res. Jun. 1998;21(2):241-5. Not eligible outcomes. [pmid: 9924686].
3703 Rintala R, Lahdenne P, Lindahl H, et al. Anorectal function in adults operated for a benign sacrococcygeal teratoma. J Pediatr Surg. Sep. 1993;28(9):1165-7. Not eligible exposure. [pmid: 8308684].
3704 Rintala RJ, Lindahl HG. Fecal continence in patients having undergone posterior sagittal anorectoplasty procedure for a high anorectal malformation improves at adolescence, as constipation disappears. J Pediatr Surg. Aug. 2001;36(8):1218-21. Not eligible target population. [pmid: 11479860].
3705 Ripetti V, Caputo D, Ausania F, et al. Sacral nerve neuromodulation improves physical, psychological and social quality of life in patients with fecal incontinence. Tech Coloproctol. Dec. 2002;6(3):147-52. Not eligible target population. [pmid: 12525907].
3706 Rivas DA, Karasick S, Chancellor MB. Cutaneous ileocystostomy (a bladder chimney) for the treatment of severe neurogenic vesical dysfunction. Paraplegia. Sep. 1995;33(9):530-5. Case-series. [pmid: 8524606].
3707 Rizk DE, Abadir MN, Thomas LB, et al. Determinants of the length of episiotomy or spontaneous posterior perineal lacerations during vaginal birth. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):395-400. Not eligible outcomes. [pmid: 15660183].
3708 Rizk DE, Helal TE, Mason N, et al. Non-evidence of estrogen receptors in the rectal mucosa. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(3):136-9. Not eligible outcomes. [pmid: 9745971].
3709 Rizk DE, Raaschou T, Mason N, et al. Evidence of progesterone receptors in the mucosa of the urinary bladder. Scand J Urol Nephrol. Sep. 2001;35(4):305-9. Not eligible outcomes. [pmid: 11676357].
3710 Rizk DE, Shaheen H, Thomas L, et al. The prevalence and determinants of health care-seeking behavior for urinary incontinence in United Arab Emirates women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):160-5. Not eligible outcomes. [pmid: 10430008].
3711 Rizvi RM, Nazim MH. The frequency of urinary symptoms in women attending gynaecology clinics at the Aga Khan University Hospital Karachi, Pakistan. J Pak Med Assoc. Nov. 2005;55(11):489-92. Not eligible target population. [pmid: 16304869].
3712 Roberts PL, Coller JA, Schoetz DJ Jr, et al. Manometric assessment of patients with obstetric injuries and fecal incontinence. Dis Colon Rectum. Jan. 1990;33(1):16-20. Case-series. [pmid: 2295272].
3713 Robinson BE, Barry PP, Renick N, et al. Physician confidence and interest in learning more about common geriatric topics: a needs assessment. J Am Geriatr Soc. Jul. 2001;49(7):963-7. Not eligible outcomes. [pmid: 11527489].
3714 Robinson D, Bidmead J, Cardozo L, et al. An unusual cause of voiding dysfunction following colposuspension. J Obstet Gynaecol. Mar. 2003;23(2):210-1. Case Reports. [pmid: 12745573].
3715 Robinson D, Cardozo L, Akeson M, et al. Antidiuresis: a new concept in managing female daytime urinary incontinence. BJU Int. May. 2004;93(7):996-1000. Not eligible exposure. [pmid: 15142150].
3716 Robinson D, Savvas M, Cardozo L. An unusual cause of ‘incontinence’ after hysterectomy. BJU Int. May. 2003;91(7):727-8. Case report. [pmid: 12699495].
3717 Robinson JP. Phases of the qualitative research interview with institutionalized elderly individuals. J Gerontol Nurs. Nov. 2000;26(11):17-23. Not eligible outcomes.
3718 Robinson JP, Shea JA. Development and testing of a measure of health-related quality of life for men with urinary incontinence. J Am Geriatr Soc. May. 2002;50(5):935-45. Not eligible outcomes. [pmid: 12028184].
3719 Robinson JW, Donnelly BJ, Coupland K, et al. Quality of life 2 years after salvage cryosurgery for the treatment of local recurrence of prostate cancer after radiotherapy. Urol Oncol. Nov–Dec. 2006;24(6):472-86. Case-series. [pmid: 17138127].
3720 Rocco F, Carmignani L, Acquati P, et al. Restoration of posterior aspect of rhabdosphincter shortens continence time after radical retropubic prostatectomy. J Urol. Jun. 2006;175(6):2201-6. Case series. [pmid: 16697841].
3721 Rociu E, Stoker J, Eijkemans MJ, et al. Fecal incontinence: endoanal US versus endoanal MR imaging. Radiology. Aug. 1999;212(2):453-8. Case-series. [pmid: 10429703].
3722 Rockner G. Urinary incontinence after perineal trauma at childbirth. Scand J Caring Sci. 1990;4(4):169-72. Question 2. [pmid: 2293286].
3723 Rockwood TH, Church JM, Fleshman JW, et al. Patient and surgeon ranking of the severity of symptoms associated with fecal incontinence: the fecal incontinence severity index. Dis Colon Rectum. Dec. 1999;42(12):1525-32. Not eligible outcomes. [pmid: 10613469].
3724 Rodrigues P, Hering F, Meler A, et al. Pubo-fascial versus vaginal sling operation for the treatment of stress urinary incontinence: a prospective study. Neurourol Urodyn. 2004;23(7):627-31. Case-series. [pmid: 15382188].
3725 Rodriguez LV, Blander DS, Dorey F, et al. Discrepancy in patient and physician perception of patient's quality of life related to urinary symptoms. Urology. Jul. 2003;62(1):49-53. Case-series. [pmid: 12837421].
3726 Rodriguez LV, Bukkapatnam R, Shah SM, et al. Transvaginal paravaginal repair of high-grade cystocele central and lateral defects with concomitant suburethral sling: report of early results, outcomes, and patient satisfaction with a new technique. Urology. Nov. 2005;66(5 Suppl):57-65. Case-series. [pmid: 16194709].
3727 Rodriguez LV, Raz S. Prospective analysis of patients treated with a distal urethral polypropylene sling for symptoms of stress urinary incontinence: surgical outcome and satisfaction determined by patient driven questionnaires. J Urol. Sep. 2003;170(3):857-63. discussion 63. Case-series. [pmid: 12913716].
3728 Rodriguez-Tellez M, Herrerias JM Jr, Arguelles F, et al. Accidental intrarectal administration of alcohol enema induces proctocolitis and fecal incontinence. Endoscopy. Jul. 2001;33(7):641. Case Reports. [pmid: 11473340].
3729 Roe B. Effective and ineffective management of incontinence: issues around illness trajectory and health care. Qual Health Res. Sep. 2000;10(5):677-90. Comment. [pmid: 11066872].
3730 Roe B, Doll H, Wilson K. Help seeking behaviour and health and social services utilisation by people suffering from urinary incontinence. Int J Nurs Stud. Jun. 1999;36(3):245-53. Not eligible level of evidence. [pmid: 10404294].
3731 Roe B, May C. Incontinence and sexuality: findings from a qualitative perspective. J Adv Nurs. Sep. 1999;30(3):573-9. Not eligible outcomes. [pmid: 10499213].
3732 Roe B, Wilson K, Doll H. Public awareness and health education: findings from an evaluation of health services for incontinence in England. Int J Nurs Stud. Feb. 2001;38(1):79-89. Not eligible level of evidence. [pmid: 11137726].
3733 Roe BH. Development of Continence Advisory Services in the United Kingdom. Scand J Caring Sci. 1990;4(2):51-4. Review. [pmid: 2392621].
3734 Roe BH. What choices in care for the incontinent?. World Health Forum. 1992;13(1):81-3. Review. [pmid: 1637481].
3735 Roehl B, Buchanan EM. Urinary incontinence evaluation and the utility of pessaries in older women. Care Manag J. Winter. 2006;7(4):213-7. Review. [pmid: 17194058].
3736 Roehrborn CG, Abrams P, Rovner ES, et al. Efficacy and tolerability of tolterodine extended-release in men with overactive bladder and urgency urinary incontinence. BJU Int. May. 2006;97(5):1003-6. Not eligible exposure. [pmid: 16643482].
3737 Roenneburg ML, Wheeless CR Jr. Traumatic absence of the proximal urethra. Am J Obstet Gynecol. Dec. 2005;193(6):2169-72. Case-series. [pmid: 16325636].
3738 Rogers E, Ohori M, Kassabian VS, et al. Salvage radical prostatectomy: outcome measured by serum prostate specific antigen levels. J Urol. Jan. 1995;153(1):104-10. Case-series. [pmid: 7526002].
3739 Rogers GR, Villarreal A, Kammerer-Doak D, et al. Sexual function in women with and without urinary incontinence and/or pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(6):361-5. Not eligible outcomes. [pmid: 11795636].
3740 Rogers RG, Coates KW, Kammerer-Doak D, et al. A short form of the Pelvic Organ Prolapse/Urinary Incontinence Sexual Questionnaire (PISQ-12). Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):164-8. discussion 8. Not eligible outcomes. [pmid: 12955337].
3741 Rogers RG, Kammerer-Doak D, Darrow A, et al. Sexual function after surgery for stress urinary incontinence and/or pelvic organ prolapse: a multicenter prospective study. Am J Obstet Gynecol. Jul. 2004;191(1):206-10. Not eligible outcomes. [pmid: 15295367].
3742 Rogers RG, Kammerer-Doak D, Darrow A, et al. Does sexual function change after surgery for stress urinary incontinence and/or pelvic organ prolapse? A multicenter prospective study. Am J Obstet Gynecol. Nov. 2006;195(5):e1-4. Case-series. [pmid: 16813740].
3743 Rogers RG, Kammerer-Doak D, Olsen A, et al. A randomized, double-blind, placebo-controlled comparison of the effect of nitrofurantoin monohydrate macrocrystals on the development of urinary tract infections after surgery for pelvic organ prolapse and/or stress urinary incontinence with suprapubic catheterization. Am J Obstet Gynecol. Jul. 2004;191(1):182-7. Not eligible outcomes. [pmid: 15295362].
3744 Rogers RG, Lebkuchner U, Kammerer-Doak DN, et al. Obesity and retropubic surgery for stress incontinence: is there really an increased risk of intraoperative complications?. Am J Obstet Gynecol. Dec. 2006;195(6):1794-8. Not eligible outcomes. [pmid: 17014816].
3745 Roghmann MC, Wallin MT, Gorman PH, et al. Prevalence and natural history of colonization with fluoroquinolone-resistant gram-negative bacilli in community-dwelling people with spinal cord dysfunction. Arch Phys Med Rehabil. Oct. 2006;87(10):1305-9. Not eligible outcomes. [pmid: 17023238].
3746 Rohr G, Kragstrup J, Gaist D, et al. Genetic and environmental influences on urinary incontinence: a Danish population-based twin study of middle-aged and elderly women. Acta Obstet Gynecol Scand. Oct. 2004;83(10):978-82. Not eligible level of evidence. [pmid: 15453898].
3747 Roig JV, Buch E, Alos R, et al. Anorectal function in patients with complete rectal prolapse. Differences between continent and incontinent individuals. Rev Esp Enferm Dig. Nov. 1998;90(11):794-805. Not eligible outcomes. [pmid: 9866412].
3748 Roig JV, Villoslada C, Lledo S, et al. Prevalence of pudendal neuropathy in fecal incontinence. Results of a prospective study. Dis Colon Rectum. Sep. 1995;38(9):952-8. Not eligible exposure. [pmid: 7656743].
3749 Rollins G. Behavior management improves urinary incontinence in older women living at home. Rep Med Guidel Outcomes Res. Mar 8. 2002;13(5):7-9. News.
3750 Romano G, La Torre F, Cutini G, et al. Total anorectal reconstruction with the artificial bowel sphincter: report of eight cases. A quality-of-life assessment. Dis Colon Rectum. Jun. 2003;46(6):730-4. Case-series. [pmid: 12794573].
3751 Romano G, Rotondano G, Esposito P, et al. External anal sphincter defects: correlation between pre-operative anal endosonography and intraoperative findings. Br J Radiol. Jan. 1996;69(817):6-9. Case-series. [pmid: 8785623].
3752 Romano SV, Metrebian SE, Vaz F, et al. An adjustable male sling for treating urinary incontinence after prostatectomy: a phase III multicentre trial. BJU Int. Mar. 2006;97(3):533-9. Case-series. [pmid: 16469021].
3753 Romanzi LJ. Urinary incontinence: a family affair. J Gend Specif Med. Oct–Nov. 1998;1(2):52-3. Comment. [pmid: 11281013].
3754 Romanzi LJ, Groutz A, Blaivas JG. Urethral diverticulum in women: diverse presentations resulting in diagnostic delay and mismanagement. J Urol. Aug. 2000;164(2):428-33. Case-series. [pmid: 10893602].
3755 Rondorf-Klym LM, Colling J. Quality of life after radical prostatectomy. Oncol Nurs Forum. Mar–Apr. 2003;30(2):E24-32. Not eligible outcomes. [pmid: 12692667].
3756 Rondorf-Klym LM, Colling J, Simonson W. Medication use by community-dwelling elderly with urinary incontinence. Urol Nurs. Sep. 1998;18(3):201-6. Not eligible outcomes. [pmid: 9873364].
3757 Rongen MJ, Uludag O, El Naggar K, et al. Long-term follow-up of dynamic graciloplasty for fecal incontinence. Dis Colon Rectum. Jun. 2003;46(6):716-21. Case-series. [pmid: 12794571].
3758 Ronnblom A, Forsberg H, Danielsson A. Gastrointestinal symptoms in myotonic dystrophy. Scand J Gastroenterol. Jul. 1996;31(7):654-7. Case-series. [pmid: 8819213].
3759 Roovers JP, van der Bom JG, van der Vaart CH, et al. Abdominal versus vaginal approach for the management of genital prolapse and coexisting stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(4):224-31. Case-series. [pmid: 12189427].
3760 Rose MA, Baigis-Smith J, Smith D, et al. Behavioral management of urinary incontinence in homebound older adults. Home Healthc Nurse. Sep–Oct. 1990;8(5):10-5. Comment.
3761 Rosen HR, Novi G, Zoech G, et al. Restoration of anal sphincter function by single-stage dynamic graciloplasty with a modified (split sling) technique. Am J Surg. Mar. 1998;175(3):187-93. Case-series. [pmid: 9560117].
3762 Rosen HR, Urbarz C, Holzer B, et al. Sacral nerve stimulation as a treatment for fecal incontinence. Gastroenterology. Sep. 2001;121(3):536-41. Not eligible target population. [pmid: 11522736].
3763 Rosenberg J, Kehlet H. Early discharge after external anal sphincter repair. Dis Colon Rectum. Apr. 1999;42(4):457-9. Case-series. [pmid: 10215044].
3764 Rosenberg LJ, Griffiths DJ, Resnick NM. Factors that distinguish continent from incontinent older adults with detrusor overactivity. J Urol. Nov. 2005;174(5):1868-72. Not eligible outcomes. [pmid: 16217326].
3765 Rosenblum N, Scarpero HM, Nitti VW. Voiding dysfunction in young, nulliparous women: symptoms and urodynamic findings. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2004;15(6):373-7. discussion 7. Not eligible outcomes. [pmid: 15278258].
3766 Rosenzweig BA, Hischke D, Thomas S, et al. Stress incontinence in women. Psychological status before and after treatment. J Reprod Med. Dec. 1991;36(12):835-8. Not eligible exposure. [pmid: 1816393].
3767 Rosenzweig BA, Pushkin S, Blumenfeld D, et al. Prevalence of abnormal urodynamic test results in continent women with severe genitourinary prolapse. Obstet Gynecol. Apr. 1992;79(4):539-42. Not eligible outcomes. [pmid: 1553172].
3768 Roshkow JE, Ng CC. Pelvic mucocele following colostomy: CT and ultrasound findings. J Comput Assist Tomogr. Nov–Dec. 1990;14(6):1022-3. Case Reports. [pmid: 2229551].
3769 Ross JW. Multichannel urodynamic evaluation of laparoscopic Burch colposuspension for genuine stress incontinence. Obstet Gynecol. Jan. 1998;91(1):55-9. Case-series. [pmid: 9464721].
3770 Ross JW. Numerous indications for office flexible minihysteroscopy. J Am Assoc Gynecol Laparosc. May. 2000;7(2):221-6. Not eligible outcomes. [pmid: 10806266].
3771 Ross JW. Laparoscopic Burch colposuspension and overlapping sphincteroplasty for double incontinence. Jsls. Jul–Sep. 2001;5(3):203-9. Case-series. [pmid: 11548823].
3772 Ross JW, Galen DI, Abbott K, et al. A prospective multisite study of radiofrequency bipolar energy for treatment of genuine stress incontinence. J Am Assoc Gynecol Laparosc. Nov. 2002;9(4):493-9. Not eligible exposure. [pmid: 12386362].
3773 Rossignol G, Leandri P, Gautier JR, et al. Radical retropubic prostatectomy: complications and quality of life (429 cases, 1983-1989). Eur Urol. 1991;19(3):186-91. Case series. [pmid: 1855524].
3774 Rossignol G, Leandri P, Ramon J, et al. Radical prostatectomy in the management of stage-A carcinoma of the prostate. Eur Urol. 1991;20(3):179-83. Not eligible level of evidence. [pmid: 1823039].
3775 Rothbarth J, Bemelman WA, Meijerink WJ, et al. Long-term results of anterior anal sphincter repair for fecal incontinence due to obstetric injury / with invited commentaries. Dig Surg. 2000;17(4):390-3. discussion 4. Case-series. [pmid: 11053947].
3776 Rothbarth J, Bemelman WA, Meijerink WJ, et al. What is the impact of fecal incontinence on quality of life?. Dis Colon Rectum. Jan. 2001;44(1):67-71. Case-series. [pmid: 11805565].
3777 Rouanet P, Senesse P, Bouamrirene D, et al. Anal sphincter reconstruction by dynamic graciloplasty after abdominoperineal resection for cancer. Dis Colon Rectum. Apr. 1999;42(4):451-6. Case-series. [pmid: 10215043].
3778 Roumeguere T, Quackels T, Bollens R, et al. Trans-obturator vaginal tape (TOT) for female stress incontinence: one year follow-up in 120 patients. Eur Urol. Nov. 2005;48(5):805-9. Case-series. [pmid: 16182440].
3779 Rousseau P, Fuentevilla-Clifton A. Acetazolamide and salicylate interaction in the elderly: a case report. J Am Geriatr Soc. Aug. 1993;41(8):868-9. Case- Reports. [pmid: 8340566].
3780 Routh JC, Crimmins CR, Leibovich BC, et al. Impact of Parkinson's disease on continence after radical prostatectomy. Urology. Sep. 2006;68(3):575-7. Case-series. [pmid: 16979722].
3781 Rovner ES, Gomes CM, Banner MP, et al. Ventral hernia of the urinary bladder with mixed urinary incontinence: treatment with herniorrhaphy and allograft fascial sling. Urology. Jan. 2000;55(1):145. Case Reports.
3782 Rovner ES, Wein AJ. Modern pharmacotherapy of urge urinary incontinence in the USA: tolterodine and oxybutynin. BJU Int. Oct. 2000;86(Suppl 2):44-53. discussion -4. Review. [pmid: 11501617].
3783 Roy S. The cost of continence. Elder Care. 1997 Dec–1998 Jan;9(6 Suppl):3-4. Comment.
3784 Roy S. Continence. Services for a new century. Nurs Times. Oct 20–26. 1999;95(42):65-7. Comment. [pmid: 10788893].
3785 Rozet F, Mandron E, Arroyo C, et al. Laparoscopic sacral colpopexy approach for genito-urinary prolapse: experience with 363 cases. Eur Urol. Feb. 2005;47(2):230-6. Not eligible level of evidence. [pmid: 15661419].
3786 Rozmovits L, Ziebland S. Expressions of loss of adulthood in the narratives of people with colorectal cancer. Qual Health Res. Feb. 2004;14(2):187-203. No associative hypothesis tested. [pmid: 14768457].
3787 Rubens DJ, Strang JG, Bogineni-Misra S, et al. Transperineal sonography of the rectum: anatomy and pathology revealed by sonography compared with CT and MR imaging. AJR Am J Roentgenol. Mar. 1998;170(3):637-42. Not eligible exposure. [pmid: 9490944].
3788 Rubenstein JN, Hairston JC, Eggener SE, et al. Irritative voiding symptoms and microscopic hematuria caused by intraperitoneal calcified fat necrosis. Urology. Mar. 2002;59(3):444. Case report.
3789 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. J Am Geriatr Soc. Feb. 2007;55(2):166-74. Case Reports. [pmid: 17302651].
3790 Ruby CM, Hanlon JT, Fillenbaum GG, et al. Medication use and control of urination among community-dwelling older adults. J Aging Health. Oct. 2005;17(5):661-74. Not eligible level of evidence. [pmid: 16177455].
3791 Rudy D, Cline K, Harris R, et al. Time to onset of improvement in symptoms of overactive bladder using antimuscarinic treatment. BJU Int. Mar. 2006;97(3):540-6. Not eligible exposure. [pmid: 16469022].
3792 Rudy D, Cline K, Harris R, et al. Multicenter phase III trial studying trospium chloride in patients with overactive bladder. Urology. Feb. 2006;67(2):275-80. Not eligible exposure. [pmid: 16461077].
3793 Ruff CC, van Rijswijk L, Okoli A. The impact of urinary incontinence in African American women. Ostomy Wound Manage. Dec. 2002;48(12):52-8. Not eligible target population.
3794 Ruiz-Deya G, Davis R, Srivastav SK, et al. Outpatient radical prostatectomy: impact of standard perineal approach on patient outcome. J Urol. Aug. 2001;166(2):581-6. Not eligible level of evidence. [pmid: 11458072].
3795 Rullier E, McBride T, Zerbib F, et al. Total anorectal and partial vaginal reconstruction with dynamic graciloplasty and colonic vaginoplasty after extended abdominoperineal resection: report of a case. Dis Colon Rectum. Aug. 1999;42(8):1097-101. Case Reports. [pmid: 10458139].
3796 Rullier E, Zerbib F, Marrel A, et al. Validation of the French version of the Fecal Incontinence Quality-of-Life (FIQL) scale. Gastroenterol Clin Biol. Jun–Jul. 2004;28(67 Pt 1):562-8. Not eligible exposure. [pmid: 15243389].
3797 Ruseler-van Embden JG, van Lieshout LM, Smits SA, et al. Potato tuber proteins efficiently inhibit human faecal proteolytic activity: implications for treatment of peri-anal dermatitis. Eur J Clin Invest. Apr. 2004;34(4):303-11. Not eligible target population. [pmid: 15086363].
3798 Russell AL, Grigo HM, Joseph NS, et al. Evaluating the performance of pelvic floor exercises in women with urinary incontinence. J Reprod Med. Jul. 2005;50(7):529-32. Not eligible target population. [pmid: 16130851].
3799 Russo A, Botten R, Kong MF, et al. Effects of acute hyperglycaemia on anorectal motor and sensory function in diabetes mellitus. Diabet Med. Feb. 2004;21(2):176-82. Not eligible exposure. [pmid: 14984454].
3800 Rutman MP, Deng DY, Shah SM, et al. Spiral sling salvage anti-incontinence surgery in female patients with a nonfunctional urethra: technique and initial results. J Urol. May. 2006;175(5):1794-8. discussion 8–9. Not eligible target population. [pmid: 16600764].
3801 Rutner AB, Levine SR, Schmaelzle JF. Processed porcine small intestine submucosa as a graft material for pubovaginal slings: durability and results. Urology. Nov. 2003;62(5):805-9. Case-series. [pmid: 14624898].
3802 Ruud Bosch JL, Groen J. Treatment of refractory urge urinary incontinence with sacral spinal nerve stimulation in multiple sclerosis patients. Lancet. Sep 14. 1996;348(9029):717-9. Case-series. [pmid: 8806291].
3803 Ryan PD, Harisinghani M, Lerwill MF, et al. Case records of the Massachusetts General Hospital. Case 6-2006. A 71-year-old woman with urinary incontinence and a mass in the bladder. N Engl J Med. Feb 23. 2006;354(8):850-6. Case Reports. [pmid: 16495398].
3804 Ryhammer AM, Bek KM, Laurberg S. Multiple vaginal deliveries increase the risk of permanent incontinence of flatus urine in normal premenopausal women. Dis Colon Rectum. Nov. 1995;38(11):1206-9. Not eligible outcomes. [pmid: 7587765].
3805 Ryhammer AM, Laurberg S, Bek KM. Age and anorectal sensibility in normal women. Scand J Gastroenterol. Mar. 1997;32(3):278-84. Not eligible exposure. [pmid: 9085467].
3806 Ryhammer AM, Laurberg S, Djurhuus JC, et al. No relationship between subjective assessment of urinary incontinence and pad test weight gain in a random population sample of menopausal women. J Urol. Mar. 1998;159(3):800-3. Not eligible outcomes. [pmid: 9474152].
3807 Ryhammer AM, Laurberg S, Hermann AP. Long-term effect of vaginal deliveries on anorectal function in normal perimenopausal women. Dis Colon Rectum. Aug. 1996;39(8):852-9. Not eligible outcomes. [pmid: 8756839].
3808 Ryhammer AM, Laurberg S, Hermann AP. No correlation between perineal position and pudendal nerve terminal motor latency in healthy perimenopausal women. Dis Colon Rectum. Mar. 1998;41(3):350-3. Not eligible outcomes. [pmid: 9514431].
3809 Ryhammer AM, Laurberg S, Sorensen FH. Effects of age on anal function in normal women. Int J Colorectal Dis. 1997;12(4):225-9. Case-series. [pmid: 9272452].
3810 Ryn AK, Morren GL, Hallbook O, et al. Long-term results of electromyographic biofeedback training for fecal incontinence. Dis Colon Rectum. Sep. 2000;43(9):1262-6. Not eligible target population. [pmid: 11005494].
3811 Sabnis RB, Bapat SD, Desai RM, et al. Experience of continent urinary diversion with modified Koff's technique. Arch Esp Urol. May. 1992;45(4):383-6. Case Reports. [pmid: 1534984].
3812 Sackier JM, Berci G, Hiatt JR, et al. Laparoscopic abdominoperineal resection of the rectum. Br J Surg. Nov. 1992;79(11):1207-8. Case Reports. [pmid: 1467906].
3813 Safarinejad MR, Hosseini SY. Safety and efficacy of tramadol in the treatment of idiopathic detrusor overactivity: a double-blind, placebo-controlled, randomized study. Br J Clin Pharmacol. Apr. 2006;61(4):456-63. Not eligible exposure. [pmid: 16542207]. [pmcid: 1885039].
3814 Safir MH, Gousse AE, Rovner ES, et al. 4-Defect repair of grade 4 cystocele. J Urol. Feb. 1999;161(2):587-94. Case-series. [pmid: 9915454].
3815 Sagar PM, Holdsworth PJ, Johnston D. Correlation between laboratory findings and clinical outcome after restorative proctocolectomy: serial studies in 20 patients with end-to-end pouch-anal anastomosis. Br J Surg. Jan. 1991;78(1):67-70. Case-series. [pmid: 1998869].
3816 Sahadevan S, Lim PP, Choo PW. Dementia in the hospitalized elderly—a study of 100 consecutive cases in Singapore. Int J Geriatr Psychiatry. Apr. 1999;14(4):266-71. Case-series. [pmid: 10340187].
3817 Saigal CS, Gornbein J, Reid K, et al. Stability of time trade-off utilities for health states associated with the treatment of prostate cancer. Qual Life Res. Aug. 2002;11(5):405-14. Not eligible level of evidence. [pmid: 12113388].
3818 Saigusa N, Belin BM, Choi HJ, et al. Recovery of the rectoanal inhibitory reflex after restorative proctocolectomy: does it correlate with nocturnal continence?. Dis Colon Rectum. Feb. 2003;46(2):168-72. Case-series. [pmid: 12576889].
3819 Sailer M, Bussen D, Debus ES, et al. Quality of life in patients with benign anorectal disorders. Br J Surg. Dec. 1998;85(12):1716-9. Not eligible outcomes. [pmid: 9876082].
3820 Saini J, Axelrod FB, Maayan C, et al. Urinary incontinence in familial dysautonomia. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):209-13. discussion 13. Case-series. [pmid: 12955345].
3821 Sainio AP, Halme LE, Husa AI. Anal encirclement with polypropylene mesh for rectal prolapse and incontinence. Dis Colon Rectum. Oct. 1991;34(10):905-8. Case-series. [pmid: 1914725].
3822 Sainio AP, Voutilainen PE, Husa AI. Recovery of anal sphincter function following transabdominal repair of rectal prolapse: cause of improved continence?. Dis Colon Rectum. Sep. 1991;34(9):816-21. Case-series. [pmid: 1914749].
3823 Saint S, Kaufman SR, Rogers MA, et al. Condom versus indwelling urinary catheters: a randomized trial. J Am Geriatr Soc. Jul. 2006;54(7):1055-61. Not eligible outcomes. [pmid: 16866675].
3824 Saito M, Kawatani M, Kinoshita Y, et al. Effectiveness of an anti-inflammatory drug, loxoprofen, for patients with nocturia. Int J Urol. Aug. 2005;12(8):779-82. Not eligible target population. [pmid: 16174058].
3825 Saito M, Watanabe T, Tabuchi F, et al. Urodynamic effects and safety of modified intravesical oxybutynin chloride in patients with neurogenic detrusor overactivity: 3 years experience. Int J Urol. Aug. 2004;11(8):592-6. Not eligible target population. [pmid: 15285747].
3826 Saito S, Murakami G. Radical perineal prostatectomy: a novel approach for lymphadenectomy from perineal incision. J Urol. Oct. 2003;170(4 Pt 1):1298-300. Case-series. [pmid: 14501746].
3827 Sakai I, Harada K, Hara I, et al. Intussusception of the bladder neck does not promote early restoration to urinary continence after non-nerve-sparing radical retropubic prostatectomy. Int J Urol. Mar. 2005;12(3):275-9. Case-series. [pmid: 15828955].
3828 Sakakibara R, Hattori T, Boku K, et al. Micturitional disturbance in neuro-Behcet's syndrome. Auton Neurosci. Sep 1. 2000;83(12):86-9. Case-series. [pmid: 11023633].
3829 Sakakibara R, Hattori T, Fukutake T, et al. Micturitional disturbance in a patient with adrenomyeloneuropathy (AMN). Neurourol Urodyn. 1998;17(3):207-12. Case Reports. [pmid: 9590472].
3830 Sakakibara R, Hattori T, Kita K, et al. Stress induced urinary incontinence in patients with spinocerebellar degeneration. J Neurol Neurosurg Psychiatry. Mar. 1998;64(3):389-91. Not eligible level of evidence. [pmid: 9527157]. [pmcid: 2169986].
3831 Sakakibara R, Hattori T, Tojo M, et al. Micturitional disturbance in progressive supranuclear palsy. J Auton Nerv Syst. Nov. 1993;45(2):101-6. Case-series. [pmid: 8282945].
3832 Sakakibara R, Hattori T, Tojo M, et al. Micturitional disturbance in multiple system atrophy. Jpn J Psychiatry Neurol. Sep. 1993;47(3):591-8. Not eligible exposure. [pmid: 8301874].
3833 Sakakibara R, Hattori T, Tojo M, et al. Micturitional disturbance in radiation myelopathy. J Spinal Disord. Oct. 1993;6(5):402-5. Case-series. [pmid: 8274808].
3834 Sakakibara R, Hattori T, Tojo M, et al. The location of the paths subserving micturition: studies in patients with cervical myelopathy. J Auton Nerv Syst. Nov 6. 1995;55(3):165-8. Not eligible level of evidence. [pmid: 8801266].
3835 Sakakibara R, Hattori T, Uchiyama T, et al. Micturitional disturbance in pure autonomic failure. Neurology. Jan 25. 2000;54(2):499-501. Case-series. [pmid: 10668724].
3836 Sakakibara R, Hattori T, Uchiyama T, et al. Uroneurological assessment of spina bifida cystica and occulta. Neurourol Urodyn. 2003;22(4):328-34. Not eligible target population. [pmid: 12808708].
3837 Sakakibara R, Hattori T, Uchiyama T, et al. Urinary function in elderly people with and without leukoaraiosis: relation to cognitive and gait function. J Neurol Neurosurg Psychiatry. Nov. 1999;67(5):658-60. Case-series. [pmid: 10519875]. [pmcid: 1736610].
3838 Sakakibara R, Hattori T, Uchiyama T, et al. Micturitional disturbance in a patient with neurosarcoidosis. Neurourol Urodyn. 2000;19(3):273-7. Case Reports. [pmid: 10797584].
3839 Sakakibara R, Hattori T, Uchiyama T, et al. Videourodynamic and sphincter motor unit potential analyses in Parkinson's disease and multiple system atrophy. J Neurol Neurosurg Psychiatry. Nov. 2001;71(5):600-6. Not eligible exposure. [pmid: 11606669]. [pmcid: 1737611].
3840 Sakakibara R, Hattori T, Uchiyama T, et al. Micturitional disturbance in subacute myelo-optico-neuropathy (SMON). Auton Neurosci. Mar 23. 2001;87(23):282-5. Case-series. [pmid: 11476290].
3841 Sakakibara R, Hattori T, Yasuda K, et al. Micturitional disturbance after acute hemispheric stroke: analysis of the lesion site by CT and MRI. J Neurol Sci. Apr. 1996;137(1):47-56. Case-series. [pmid: 9120487].
3842 Sakakibara R, Hattori T, Yasuda K, et al. Micturitional disturbance in acute disseminated encephalomyelitis (ADEM). J Auton Nerv Syst. Sep 12. 1996;60(3):200-5. Case-series. [pmid: 8912271].
3843 Sakakibara R, Hattori T, Yasuda K, et al. Micturitional disturbance in Wernicke's encephalopathy. Neurourol Urodyn. 1997;16(2):111-5. Case Reports. [pmid: 9042673].
3844 Sakakibara R, Ito T, Uchiyama T, et al. Lower urinary tract function in dementia of Lewy body type. J Neurol Neurosurg Psychiatry. May. 2005;76(5):729-32. Not eligible exposure. [pmid: 15834036]. [pmcid: 1739636].
3845 Sakakibara R, Odaka T, Uchiyama T, et al. Colonic transit time, sphincter EMG, and rectoanal videomanometry in multiple system atrophy. Mov Disord. Aug. 2004;19(8):924-9. Not eligible exposure. [pmid: 15300657].
3846 Sakakibara R, Uchiyama T, Yamanishi T, et al. Urinary function in patients with corticobasal degeneration; comparison with normal subjects. Neurourol Urodyn. 2004;23(2):154-8. Not eligible level of evidence. [pmid: 14983428].
3847 Sakakibara R, Uchiyama T, Yoshiyama M, et al. Micturitional disturbance in a patient with a spinal cavernous angioma. Neurourol Urodyn. 2003;22(6):606-10. Case- Reports. [pmid: 12951673].
3848 Sakakibara R, Uchiyama T, Yoshiyama M, et al. Preliminary communication: urodynamic assessment of donepezil hydrochloride in patients with Alzheimer's disease. Neurourol Urodyn. 2005;24(3):273-5. Case-series. [pmid: 15605367].
3849 Sakuragi N, Todo Y, Kudo M, et al. A systematic nerve-sparing radical hysterectomy technique in invasive cervical cancer for preserving postsurgical bladder function. Int J Gynecol Cancer. Mar–Apr. 2005;15(2):389-97. Case-series. [pmid: 15823132].
3850 Sale PG, Wyman JF. Achievement of goals associated with bladder training by older incontinent women. Appl Nurs Res. May. 1994;7(2):93-6. Comment. [pmid: 8031113].
3851 Salemans JM, Nagengast FM, Lubbers EJ, et al. Postoperative and long-term results of ileal pouch-anal anastomosis for ulcerative colitis and familial polyposis coli. Dig Dis Sci. Dec. 1992;37(12):1882-9. Case-series. [pmid: 1335407].
3852 Saliba D, Solomon D, Rubenstein L, et al. Feasibility of quality indicators for the management of geriatric syndromes in nursing home residents. J Am Med Dir Assoc. May–Jun. 2005;6(3 Suppl):S50-9. Not eligible target population. [pmid: 15890298].
3853 Saliken JC, Donnelly BJ, Brasher P, et al. Outcome and safety of transrectal US-guided percutaneous cryotherapy for localized prostate cancer. J Vasc Interv Radiol. Feb. 1999;10(2 Pt 1):199-208. Case-series. [pmid: 10082109].
3854 Salomon CG, Dudiak CM, Pyle JM, et al. Transrectal ultrasound of the prostate bed after collagen injection. J Comput Assist Tomogr. Mar–Apr. 1996;20(2):279-82. Case-series. [pmid: 8606237].
3855 Salonia A, Zanni G, Nappi RE, et al. Sexual dysfunction is common in women with lower urinary tract symptoms and urinary incontinence: results of a cross-sectional study. Eur Urol. May. 2004;45(5):642-8. discussion 8. Not eligible outcomes. [pmid: 15082208].
3856 Saltzstein L. Management of overactive bladder in a difficult-to-treat patient with a transdermal formulation of oxybutynin. Urol Nurs. Aug. 2005;25(4):260-2. Case- Reports. [pmid: 16225342].
3857 Saltzstein RJ, Romano J. The efficacy of colostomy as a bowel management alternative in selected spinal cord injury patients. J Am Paraplegia Soc. Apr. 1990;13(2):9-13. Case- Reports. [pmid: 2335780].
3858 Salvage D. Order out of chaos. Nurs Stand. Jun 14–20. 2000;14(39):20-1. Case Reports. [pmid: 11974315].
3859 Salvatore S, Khullar V, Cardozo L, et al. Long-term prospective randomized study comparing two different regimens of oxybutynin as a treatment for detrusor overactivity. Eur J Obstet Gynecol Reprod Biol. Apr 1. 2005;119(2):237-41. Not eligible exposure. [pmid: 15808387].
3860 Salvioli B, Bharucha AE, Rath-Harvey D, et al. Rectal compliance, capacity, and rectoanal sensation in fecal incontinence. Am J Gastroenterol. Jul. 2001;96(7):2158-68. Not eligible outcomes. [pmid: 11467648].
3861 Samanci N, Dora B, Kizilay F, et al. Factors affecting one year mortality and functional outcome after first ever ischemic stroke in the region of Antalya, Turkey (a hospital-based study). Acta Neurol Belg. Dec. 2004;104(4):154-60. Not eligible outcomes. [pmid: 15742605].
3862 Samandari T, Smith BD, Morgan HJ. Progressive somnolence and confusion in a patient with hereditary hemorrhagic telangiectasias. Tenn Med. Nov. 1996;89(11):417-8. Case Reports. [pmid: 8942282].
3863 Samil RS, Wishnuwardhani SD. Health of Indonesian women city-dwellers of perimenopausal age. Maturitas. Oct. 1994;19(3):191-7. Not eligible outcomes. [pmid: 7799825].
3864 Samli M, Singla AK. Absorbable versus nonabsorbable graft: outcome of bone anchored male sling for post-radical prostatectomy incontinence. J Urol. Feb. 2005;173(2):499-502. Case-series. [pmid: 15643228].
3865 Sammour ZM, Gomes CM, Duarte RJ, et al. Voiding dysfunction and the Williams-Beuren syndrome: a clinical and urodynamic investigation. J Urol. Apr. 2006;175(4):1472-6. Not eligible target population. [pmid: 16516025].
3866 Sampselle CM. Changes in pelvic muscle strength and stress urinary incontinence associated with childbirth. J Obstet Gynecol Neonatal Nurs. Sep–Oct. 1990;19(5):371-7. Case-series.
3867 Sampselle CM, Messer KL, Seng JS, et al. Learning outcomes of a group behavioral modification program to prevent urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):441-6. Not eligible outcomes. [pmid: 16237512].
3868 Sampselle CM, Miller JM, Herzog AR, et al. Behavioral modification: group teaching outcomes. Urol Nurs. Jun. 1996;16(2):59-63. Comment. [pmid: 8826155].
3869 Sampselle CM, Wyman JF, Thomas KK, et al. Continence for women: a test of AWHONN's evidence-based protocol in clinical practice. Association of Women's Health Obstetric and Neonatal Nurses. J Obstet Gynecol Neonatal Nurs. Jan–Feb. 2000;29(1):18-26. Not eligible level of evidence.
3870 Sampselle CM, Wyman JF, Thomas KK, et al. Continence for women: evaluation of AWHONN's third research utilization project. Association of Women's Health Obstetric and Neonatal Nurses. J Obstet Gynecol Neonatal Nurs. Jan–Feb. 2000;29(1):9-17. Not eligible outcomes.
3871 Samsioe G, Heraib F, Lidfeldt J, et al. Urogenital symptoms in women aged 50–59 years. Women's Health in Lund Area (WHILSA) Study Group. Gynecol Endocrinol. Apr. 1999;13(2):113-7. Not eligible level of evidence. [pmid: 10399056].
3872 Samuelsson E, Mansson L, Milsom I. Incontinence aids in Sweden: users and costs. BJU Int. Dec. 2001;88(9):893-8. Not eligible outcomes. [pmid: 11851610].
3873 Sanchez de Badajoz E, Diaz Ramirez F, Vara Thorbeck C. Stress incontinence: a new endoscopic approach. Urology. Nov. 1990;36(5):403-5. Case-series. [pmid: 2238298].
3874 Sanchez-Ortiz RF, Broderick GA, Chaikin DC, et al. Collagen injection therapy for post-radical retropubic prostatectomy incontinence: role of Valsalva leak point pressure. J Urol. Dec. 1997;158(6):2132-6. [pmid: 9366329].
3875 Sand P, Zinner N, Newman D, et al. Oxybutynin transdermal system improves the quality of life in adults with overactive bladder: a multicentre, community-based, randomized study. BJU Int. Apr. 2007;99(4):836-44. Not eligible exposure. [pmid: 17187655].
3876 Sand PK, Appell R. Disruptive effects of overactive bladder and urge urinary incontinence in younger women. Am J Med. Mar. 2006;119(3 Suppl 1):16-23. Review. [pmid: 16483864].
3877 Sand PK, Goldberg RP, Dmochowski RR, et al. The impact of the overactive bladder syndrome on sexual function: a preliminary report from the Multicenter Assessment of Transdermal Therapy in Overactive Bladder with Oxybutynin trial. Am J Obstet Gynecol. Dec. 2006;195(6):1730-5. Not eligible outcomes. [pmid: 17132474].
3878 Sand PK, Miklos J, Ritter H, et al. A comparison of extended-release oxybutynin and tolterodine for treatment of overactive bladder in women. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):243-8. Not eligible exposure. [pmid: 15517668].
3879 Sand PK, Staskin D, Miller J, et al. Effect of a urinary control insert on quality of life in incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(2):100-5. Not eligible target population. [pmid: 10384971].
3880 Sander P, Bjarnesen J, Mouritsen L, et al. Anal incontinence after obstetric third-/fourth-degree laceration. One-year follow-up after pelvic floor exercises. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):177-81. Case-series. [pmid: 10430011].
3881 Sander P, Mouritsen L, Andersen JT, et al. Should measurement of maximum urinary flow rate and residual urine volume be a part of a “minimal care” assessment programme in female incontinence?. Scand J Urol Nephrol. 2002;36(2):124-7. Not eligible outcomes. [pmid: 12056406].
3882 Sander P, Thyssen H, Lose G, et al. Effect of a vaginal device on quality of life with urinary stress incontinence. Obstet Gynecol. Mar. 1999;93(3):407-11. Not eligible target population. [pmid: 10074989].
3883 Sandvik H. Criterion validity of responses to patient vignettes: an analysis based on management of female urinary incontinence. Fam Med. Jun. 1995;27(6):388-92. Not eligible target population. [pmid: 7665027].
3884 Sandvik H. Health information and interaction on the internet: a survey of female urinary incontinence. BMJ. Jul 3. 1999;319(7201):29-32. Not eligible target population. [pmid: 10390457]. [pmcid: 28152].
3885 Sandvik H, Hunskaar S. Incontinence pads—prevalence of use and individual consumption. Scand J Soc Med. Jun. 1993;21(2):120-1. Not eligible outcomes. [pmid: 8367677].
3886 Sandvik H, Hunskaar S. Incontinence in women: different response rates may introduce bias in community studies of pad consumption. J Epidemiol Community Health. Aug. 1994;48(4):419. Comment. [pmid: 7964344]. [pmcid: 1059994].
3887 Sandvik H, Hunskaar S. General practitioners' management of female urinary incontinence. Medical records do not reflect patients' recall. Scand J Prim Health Care. Sep. 1995;13(3):168-74. Not eligible outcomes. [pmid: 7481168].
3888 Sandvik H, Hunskaar S, Eriksen BC. Management of urinary incontinence in women in general practice: actions taken at the first consultation. Scand J Prim Health Care. Mar. 1990;8(1):3-8. Case- Reports. [pmid: 2356371].
3889 Sandvik H, Seim A, Vanvik A, et al. A severity index for epidemiological surveys of female urinary incontinence: comparison with 48-hour pad-weighing tests. Neurourol Urodyn. 2000;19(2):137-45. Not eligible outcomes. [pmid: 10679830].
3890 Sangalli MR, Marti MC. Results of sphincter repair in postobstetric fecal incontinence. J Am Coll Surg. Nov. 1994;179(5):583-6. Case-series. [pmid: 7952463].
3891 Sangwan YP, Coller JA, Barrett RC, et al. Distal rectoanal excitatory reflex: a reliable index of pudendal neuropathy?. Dis Colon Rectum. Sep. 1995;38(9):916-20. Not eligible exposure. [pmid: 7656737].
3892 Sangwan YP, Coller JA, Barrett RC, et al. Unilateral pudendal neuropathy. Impact on outcome of anal sphincter repair. Dis Colon Rectum. Jun. 1996;39(6):686-9. Not eligible exposure. [pmid: 8646958].
3893 Sangwan YP, Coller JA, Barrett RC, et al. Can manometric parameters predict response to biofeedback therapy in fecal incontinence?. Dis Colon Rectum. Oct. 1995;38(10):1021-5. Case-series. [pmid: 7555413].
3894 Sangwan YP, Coller JA, Schoetz DJ Jr, et al. Latency measurement of rectoanal reflexes. Dis Colon Rectum. Dec. 1995;38(12):1281-5. Question 4. [pmid: 7497840].
3895 Sangwan YP, Coller JA, Schoetz DJ Jr, et al. Relationship between manometric anal waves and fecal incontinence. Dis Colon Rectum. Apr. 1995;38(4):370-4. Not eligible outcomes. [pmid: 7720442].
3896 Sangwan YP, Coller JA, Schoetz DJ, et al. Spectrum of abnormal rectoanal reflex patterns in patients with fecal incontinence. Dis Colon Rectum. Jan. 1996;39(1):59-65. Question 4. [pmid: 8601359].
3897 Sangwan YP, Schoetz DJ Jr, Murray JJ, et al. Perianal Crohn's disease. Results of local surgical treatment. Dis Colon Rectum. May. 1996;39(5):529-35. Case-series. [pmid: 8620803].
3898 Santoro GA, Eitan BZ, Pryde A, et al. Open study of low-dose amitriptyline in the treatment of patients with idiopathic fecal incontinence. Dis Colon Rectum. Dec. 2000;43(12):1676-81. discussion 81–2. Not eligible target population. [pmid: 11156450].
3899 Santoro GA, Makhdoomi KR, Eitan BZ, et al. Functional outcome after coloanal anastomosis with J-colonic pouch for rectal cancer. Ann Ital Chir. Jul–Aug. 1998;69(4):485-9. Case-series. [pmid: 9835124].
3900 Sapin E, Centonze A, Moog R, et al. Transanal coloanal anastomosis for Hirschsprung's disease: comparison between endorectal and perirectal pull-through procedures. Eur J Pediatr Surg. Oct. 2006;16(5):312-7. Not eligible target population. [pmid: 17160774].
3901 Sapmaz E, Celik H. Burch colposuspension performed at cesarean delivery in pregnancies complicated by genuine stress urinary incontinence. J Reprod Med. Mar. 2003;48(3):191-3. Case-reports. [pmid: 12698778].
3902 Sapsford RR, Hodges PW. Contraction of the pelvic floor muscles during abdominal maneuvers. Arch Phys Med Rehabil. Aug. 2001;82(8):1081-8. Not eligible target population. [pmid: 11494188].
3903 Saraiva MM, Saraiva AM. Anal tonometry: a quick method of anal manometry. Dis Colon Rectum. May. 1991;34(5):396-400. Not eligible exposure. [pmid: 2022145].
3904 Sarli L, Pavlidis C, Cinieri FG, et al. Prospective comparison of laparoscopic left hemicolectomy for colon cancer with laparoscopic left hemicolectomy for benign colorectal disease. World J Surg. Mar. 2006;30(3):446-52. Case-series. [pmid: 16479334].
3905 Sartore A, Pregazzi R, Bortoli P, et al. The urine stream interruption test and pelvic muscle function in the puerperium. Int J Gynaecol Obstet. Sep. 2002;78(3):235-9. Not eligible outcomes. [pmid: 12384269].
3906 Sartore A, Pregazzi R, Bortoli P, et al. Perineal evaluation in the puerperium. Role of testing with a cotton-tipped swab. J Reprod Med. Aug. 2002;47(8):670-4. Not eligible outcomes. [pmid: 12216435].
3907 Sartore A, Pregazzi R, Bortoli P, et al. Assessment of pelvic floor muscle function after vaginal delivery. Clinical value of different tests. J Reprod Med. Mar. 2003;48(3):171-4. [pmid: 12698774].
3908 Sato T, Konishi F, Minakami H, et al. Pelvic floor disturbance after childbirth: vaginal delivery damages the upper levels of sphincter innervation. Dis Colon Rectum. Aug. 2001;44(8):1155-61. Not eligible outcomes. [pmid: 11535856].
3909 Sauer HA, Klutke CG. Transvaginal sacrospinous ligament fixation for treatment of vaginal prolapse. J Urol. Sep. 1995;154(3):1008-12. Case-series. [pmid: 7637043].
3910 Sauerwein D, Ingunza W, Fischer J, et al. Extradural implantation of sacral anterior root stimulators. J Neurol Neurosurg Psychiatry. Aug. 1990;53(8):681-4. Case-series. [pmid: 2213045]. [pmcid: 488172].
3911 Saunders JR, Darakhshan AA, Eccersley AJ, et al. The Colorectal Development Unit: impact on functional outcome for the electrically stimulated gracilis neoanal sphincter. Colorectal Dis. Jan. 2006;8(1):46-55. Case-series. [pmid: 16519638].
3912 Saunders JR, Eccersley AJ, Williams NS. Use of a continent colonic conduit for treatment of refractory evacuatory disorder following construction of an electrically stimulated gracilis neoanal sphincter. Br J Surg. Nov. 2003;90(11):1416-21. Case-series. [pmid: 14598424].
3913 Saunders JR, Williams NS, Eccersley AJ. The combination of electrically stimulated gracilis neoanal sphincter and continent colonic conduit: a step forward for total anorectal reconstruction?. Dis Colon Rectum. Mar. 2004;47(3):354-63. discussion 63–6. Case-series. [pmid: 14991498].
3914 Savoye G, Leroi AM, Denis P, et al. Manometric assessment of an artificial bowel sphincter. Br J Surg. May. 2000;87(5):586-9. Case-series. [pmid: 10792314].
3915 Savoye-Collet C, Savoye G, Koning E, et al. Defecographic disorders in anal incontinent women: relation to symptoms and anal endosonographic patterns. Scand J Gastroenterol. Feb. 2005;40(2):141-6. Not eligible outcomes. [pmid: 15764143].
3916 Savoye-Collet C, Savoye G, Koning E, et al. Defecography in symptomatic older women living at home. Age Ageing. May. 2003;32(3):347-50. Not eligible exposure. [pmid: 12720625].
3917 Savoye-Collet C, Savoye G, Koning E, et al. Endosonography in the evaluation of anal function after primary repair of a third-degree obstetric tear. Scand J Gastroenterol. Nov. 2003;38(11):1149-53. Case-series. [pmid: 14686718].
3918 Savoye-Collet C, Savoye G, Koning E, et al. Anal endosonography after sphincter repair: specific patterns related to clinical outcome. Abdom Imaging. Nov–Dec. 1999;24(6):569-73. Case-series. [pmid: 10525809].
3919 Saxer S, Halfens RJ, Muller M, et al. Risk factors for urinary incontinence in nursing home residents. Swiss Med Wkly. Aug 20. 2005;135(3334):495-502. Not eligible level of evidence. [pmid: 16208588].
3920 Sayegh ME, French ME. Urge incontinence secondary to a large abdominal haematoma. Br J Urol. Aug. 1995;76(2):261-2. Case Reports. [pmid: 7663925].
3921 Scarpa KP, Herrmann V, Palma PC, et al. Prevalence and correlates of stress urinary incontinence during pregnancy: a survey at UNICAMP Medical School, Sao Paulo, Brazil. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):219-23. Not eligible outcomes. [pmid: 16021326].
3922 Scarpero HM, Fiske J, Xue X, et al. American Urological Association Symptom Index for lower urinary tract symptoms in women: correlation with degree of bother and impact on quality of life. Urology. Jun. 2003;61(6):1118-22. Not eligible exposure. [pmid: 12809877].
3923 Schaal CH, Costa RP, Sala FC, et al. Longitudinal urethral sling with prepubic and retropubic fixation for male urinary incontinence. Int Braz J Urol. Jul–Aug. 2004;30(4):307-11. discussion 12. Case-series. [pmid: 15679963].
3924 Schaan M, Boszczyk B, Jaksche H, et al. Intraoperative urodynamics in spinal cord surgery: a study of feasibility. Eur Spine J. Feb. 2004;13(1):39-43. Case-series. [pmid: 14634852].
3925 Schaer GN, Koechli OR, Schuessler B, et al. Improvement of perineal sonographic bladder neck imaging with ultrasound contrast medium. Obstet Gynecol. Dec. 1995;86(6):950-4. Not eligible exposure. [pmid: 7501346].
3926 Schaer GN, Koechli OR, Schuessler B, et al. Can simultaneous perineal sonography and urethrocystometry help explain urethral pressure variations?. Neurourol Urodyn. 1997;16(1):31-8. Not eligible outcomes. [pmid: 9021788].
3927 Schaer GN, Perucchini D, Munz E, et al. Sonographic evaluation of the bladder neck in continent and stress-incontinent women. Obstet Gynecol. Mar. 1999;93(3):412-6. Not eligible outcomes. [pmid: 10074990].
3928 Schaer GN, Siegwart R, Perucchini D, et al. Examination of voiding in seated women using a remote-controlled ultrasound probe. Obstet Gynecol. Feb. 1998;91(2):297-301. Not eligible outcomes. [pmid: 9469294].
3929 Schafer A, Enck P, Heyer T, et al. Endosonography of the anal sphincters: incontinent and continent patients and healthy controls. Z Gastroenterol. Jun. 1994;32(6):328-31. Not eligible outcomes. [pmid: 7975761].
3930 Schafer R, Heyer T, Gantke B, et al. Anal endosonography and manometry: comparison in patients with defecation problems. Dis Colon Rectum. Mar. 1997;40(3):293-7. Not eligible outcomes. [pmid: 9118743].
3931 Schatz H, Henriksson L. Pain during the TVT procedure performed under local anesthesia. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):347-9. discussion 9. Case-series. [pmid: 14618314].
3932 Schatzl G, Madersbacher S, Hofbauer J, et al. The impact of urinary extravasation after radical retropubic prostatectomy on urinary incontinence and anastomotic strictures. Eur Urol. Sep. 1999;36(3):187-90. Not eligible exposure. [pmid: 10450000].
3933 Scheepens WA, Weil EH, van Koeveringe GA, et al. Buttock placement of the implantable pulse generator: a new implantation technique for sacral neuromodulation—a multicenter study. Eur Urol. Oct. 2001;40(4):434-8. Not eligible target population. [pmid: 11713399].
3934 Scheinfeld N. The legal aspects of incontinence. Ostomy Wound Manage. Dec. 2005;51(12):24-6. Comment. [pmid: 16509031].
3935 Schettini M, Fortunato P, Gallucci M. Abdominal sacral colpopexy with prolene mesh. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):295-9. Case-series. [pmid: 10543337].
3936 Scheuer M, Kuijpers HC, Bleijenberg G. Effect of electrostimulation on sphincter function in neurogenic fecal continence. Dis Colon Rectum. Jun. 1994;37(6):590-3. discussion 3–4. Case-series. [pmid: 8200239].
3937 Scheve AA, Engel BT, McCormick KA, et al. Exercise in continence. Geriatr Nurs. May–Jun. 1991;12(3):124. Comment. [pmid: 1667141].
3938 Schick E, Jolivet-Tremblay M, Tessier J, et al. Observations on the function of the female urethra: III: An overview with special reference to the relation between urethral hypermobility and urethral incompetence. Neurourol Urodyn. 2004;23(1):22-6. Not eligible outcomes. [pmid: 14694452].
3939 Schiedeck TH, Schwandner O, Scheele J, et al. Rectal prolapse: which surgical option is appropriate?. Langenbecks Arch Surg. Feb. 2005;390(1):8-14. Review. [pmid: 15004753].
3940 Schiessel R, Karner-Hanusch J, Herbst F, et al. Intersphincteric resection for low rectal tumours. Br J Surg. Sep. 1994;81(9):1376-8. Case-series. [pmid: 7953423].
3941 Schiessel R, Novi G, Holzer B, et al. Technique and long-term results of intersphincteric resection for low rectal cancer. Dis Colon Rectum. Oct. 2005;48(10):1858-65. discussion 65–7. Case-series. [pmid: 16086223].
3942 Schiff D, O'Neill BP. Intramedullary spinal cord metastases: clinical features and treatment outcome. Neurology. Oct. 1996;47(4):906-12. Case-series. [pmid: 8857717].
3943 Schiller LR. Electrifying progress for fecal incontinence. Curr Gastroenterol Rep. Oct. 2004;6(5):387-8. Comment. [pmid: 15341714].
3944 Schilling A, Krawczak G, Friesen A, et al. Pregnancy in a patient with an ileal substitute bladder followed by severe destabilization of the pelvic support. J Urol. Apr. 1996;155(4):1389-90. Case-reports. [pmid: 8632587].
3945 Schiotz HA. One month maximal electrostimulation for genuine stress incontinence in women. Neurourol Urodyn. 1994;13(1):43-50. Not eligible target population. [pmid: 8156074].
3946 Schiotz HA. Comparison of 1 and 3 days' transurethral Foley catheterization after retropubic incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):98-101. Not eligible outcomes. [pmid: 8798095].
3947 Schirm V, Baumgardner J, Dowd T, et al. Development of a healthy bladder education program for older adults. Geriatr Nurs. Sep–Oct. 2004;25(5):301-6. Not eligible outcomes. [pmid: 15486549].
3948 Schlossmacher MG, Hamann C, Cole AG, et al. Case records of the Massachusetts General Hospital. Weekly clinicopathological exercises. Case 27-2004. A 79-year-old woman with disturbances in gait, cognition, and autonomic function. N Engl J Med. Aug 26. 2004;351(9):912-22. Case- Reports. [pmid: 15329430].
3949 Schluender SJ, Mei L, Yang H, et al. Can a meta-analysis answer the question: is mucosectomy and handsewn or double-stapled anastomosis better in ileal pouch-anal anastomosis?. Am Surg. Oct. 2006;72(10):912-6. Review and meta-analysis. [pmid: 17058734].
3950 Schmid DM, Curt A, Hauri D, et al. Motor evoked potentials (MEP) and evoked pressure curves (EPC) from the urethral compressive musculature (UCM) by functional magnetic stimulation in healthy volunteers and patients with neurogenic incontinence. Neurourol Urodyn. 2005;24(2):117-27. Not eligible outcomes. [pmid: 15616965].
3951 Schmid DM, Sauermann P, Werner M, et al. Experience with 100 cases treated with botulinum-A toxin injections in the detrusor muscle for idiopathic overactive bladder syndrome refractory to anticholinergics. J Urol. Jul. 2006;176(1):177-85. Not eligible target population. [pmid: 16753396].
3952 Schmidt CM, Horton KM, Sitzmann JV, et al. Simple radiographic evaluation of ileoanal pouch volume. Dis Colon Rectum. Jan. 1996;39(1):66-73. Case-series. [pmid: 8601360].
3953 Schmidt RA. Treatment of unstable bladder. Urology. Jan. 1991;37(1):28-32. Case Reports. [pmid: 1986470].
3954 Schneider T, Sperling H, Rossi R, et al. Do early injections of bulking agents following radical prostatectomy improve early continence?. World J Urol. Nov. 2005;23(5):338-42. Case-series. [pmid: 16261366].
3955 Schnelle JF. Treatment of urinary incontinence in nursing home patients by prompted voiding. J Am Geriatr Soc. Mar. 1990;38(3):356-60. [pmid: 2313014].
3956 Schnelle JF, Adamson GM, Cruise PA, et al. Skin disorders and moisture in incontinent nursing home residents: intervention implications. J Am Geriatr Soc. Oct. 1997;45(10):1182-8. Not eligible outcomes. [pmid: 9329478].
3957 Schnelle JF, Alessi CA, Al-Samarrai NR, et al. The nursing home at night: effects of an intervention on noise, light, and sleep. J Am Geriatr Soc. Apr. 1999;47(4):430-8. Not eligible outcomes. [pmid: 10203118].
3958 Schnelle JF, Bates-Jensen BM, Chu L, et al. Accuracy of nursing home medical record information about care-process delivery: implications for staff management and improvement. J Am Geriatr Soc. Aug. 2004;52(8):1378-83. Not eligible outcomes. [pmid: 15271130].
3959 Schnelle JF, Cadogan MP, Grbic D, et al. A standardized quality assessment system to evaluate incontinence care in the nursing home. J Am Geriatr Soc. Dec. 2003;51(12):1754-61. Not eligible outcomes. [pmid: 14687354].
3960 Schnelle JF, Cadogan MP, Yoshii J, et al. The minimum data set urinary incontinence quality indicators: do they reflect differences in care processes related to incontinence?. Med Care. Aug. 2003;41(8):909-22. Not eligible level of evidence. [pmid: 12886171].
3961 Schnelle JF, Cruise PA, Alessi CA, et al. Individualizing nighttime incontinence care in nursing home residents. Nurs Res. Jul–Aug. 1998;47(4):197-204. Not eligible target population. [pmid: 9683114].
3962 Schnelle JF, Kapur K, Alessi C, et al. Does an exercise and incontinence intervention save healthcare costs in a nursing home population?. J Am Geriatr Soc. Feb. 2003;51(2):161-8. Not eligible outcomes. [pmid: 12558711].
3963 Schnelle JF, Keeler E, Hays RD, et al. A cost and value analysis of two interventions with incontinent nursing home residents. J Am Geriatr Soc. Oct. 1995;43(10):1112-7. Not eligible outcomes. [pmid: 7560701].
3964 Schnelle JF, MacRae PG, Ouslander JG, et al. Functional Incidental Training, mobility performance, and incontinence care with nursing home residents. J Am Geriatr Soc. Dec. 1995;43(12):1356-62. Not eligible outcomes. [pmid: 7490386].
3965 Schnelle JF, Smith RL. Quality indicators for the management of urinary incontinence in vulnerable community-dwelling elders. Ann Intern Med. Oct 16. 2001;135(8 Pt 2):752-8. Review. [pmid: 11601959].
3966 Scholes D, Hooton TM, Roberts PL, et al. Risk factors associated with acute pyelonephritis in healthy women. Ann Intern Med. Jan 4. 2005;142(1):20-7. Not eligible outcomes. [pmid: 15630106].
3967 Scholler-Gyure M, Nesselaar C, van Wieringen H, et al. Treatment of defecation disorders by colonic enemas in children with spina bifida. Eur J Pediatr Surg. Dec. 1996;6(Suppl 1):32-4. Not eligible target population.
3968 Schonherr MC, Groothoff JW, Mulder GA, et al. Functional outcome of patients with spinal cord injury: rehabilitation outcome study. Clin Rehabil. Dec. 1999;13(6):457-63. Case-series. [pmid: 10588531].
3969 Schostak M, Miller K, Muller M, et al. Transvaginal bone anchors in female stress urinary incontinence: poor results. Gynecol Obstet Invest. 2002;54(3):154-8. Case-series. [pmid: 12571437].
3970 Schouten WR, Briel JW, Auwerda JJ. Relationship between anal pressure and anodermal blood flow. The vascular pathogenesis of anal fissures. Dis Colon Rectum. Jul. 1994;37(7):664-9. Not eligible exposure. [pmid: 8026232].
3971 Schouten WR, Gosselink MJ, Boerma MO, et al. Rectal wall contractility in response to an evoked urge to defecate in patients with obstructed defecation. Dis Colon Rectum. Apr. 1998;41(4):473-9. Case-series. [pmid: 9559633].
3972 Schouten WR, Zimmerman DD, Briel JW. Transanal advancement flap repair of transsphincteric fistulas. Dis Colon Rectum. Nov. 1999;42(11):1419-22. discussion 22–3. Case-series. [pmid: 10566529].
3973 Schraffordt Koops SE, Bisseling TM, Heintz AP, et al. Prospective analysis of complications of tension-free vaginal tape from The Netherlands Tension-free Vaginal Tape study. Am J Obstet Gynecol. Jul. 2005;193(1):45-52. Not eligible outcomes. [pmid: 16021057].
3974 Schraffordt Koops SE, Bisseling TM, Heintz AP, et al. Quality of life before and after TVT, a prospective multicentre cohort study, results from the Netherlands TVT database. Bjog. Jan. 2006;113(1):26-9. Not eligible outcomes. [pmid: 16398767].
3975 Schulman SL, Zderic S, Kaplan P. Increased prevalence of urinary symptoms and voiding dysfunction in Williams syndrome. J Pediatr. Sep. 1996;129(3):466-9. Not eligible target population. [pmid: 8804343].
3976 Schulte-Baukloh H, Thalau F, Sturzebecher B, et al. Pubovaginal bone anchor fixation with polyethylene versus fascia lata slings in the treatment of female stress incontinence: sling material and processing are predominant factors in success. Can J Urol. Apr. 2005;12(2):2581-7. Case-series. [pmid: 15877939].
3977 Schulte-Baukloh H, Weiss C, Stolze T, et al. Botulinum-A toxin detrusor and sphincter injection in treatment of overactive bladder syndrome: objective outcome and patient satisfaction. Eur Urol. Dec. 2005;48(6):984-90. discussion 90. Not eligible target population. [pmid: 16126328].
3978 Schultheiss D, Hofner K, Oelke M, et al. Does bone anchor fixation improve the outcome of percutaneous bladder neck suspension in female stress urinary incontinence?. Br J Urol. Aug. 1998;82(2):192-5. Case-series. [pmid: 9722752].
3979 Schultz A, Talseth T. Continent urinary diversion in patients with dysfunction of the lower urinary tract. Experience with the detubularized right colonic segment as urinary reservoir. Scand J Urol Nephrol Suppl. 1996;179:93-6. Case-series. [pmid: 8908672].
3980 Schultz I, Mellgren A, Dolk A, et al. Continence is improved after the Ripstein rectopexy. Different mechanizms in rectal prolapse and rectal intussusception?. Dis Colon Rectum. Mar. 1996;39(3):300-6. Case-series. [pmid: 8603552].
3981 Schultz I, Mellgren A, Nilsson BY, et al. Preoperative electrophysiologic assessment cannot predict continence after rectopexy. Dis Colon Rectum. Nov. 1998;41(11):1392-8. Case-series. [pmid: 9823805].
3982 Schurch B, de Seze M, Denys P, et al. Botulinum toxin type a is a safe and effective treatment for neurogenic urinary incontinence: results of a single treatment, randomized, placebo controlled 6-month study. J Urol. Jul. 2005;174(1):196-200. Not eligible exposure. [pmid: 15947626].
3983 Schurch B, Reilly I, Reitz A, et al. Electrophysiological recordings during the peripheral nerve evaluation (PNE) test in complete spinal cord injury patients. World J Urol. May. 2003;20(6):319-22. Case-series. [pmid: 12811489].
3984 Schurch B, Stohrer M, Kramer G, et al. Botulinum-A toxin for treating detrusor hyperreflexia in spinal cord injured patients: a new alternative to anticholinergic drugs? Preliminary results. J Urol. Sep. 2000;164(3 Pt 1):692-7. Case-series. [pmid: 10953127].
3985 Schuur PM, Kasteren ME, Sabbe L, et al. Urinary tract infections with Aerococcus urinae in the south of The Netherlands. Eur J Clin Microbiol Infect Dis. Dec. 1997;16(12):871-5. Not eligible outcomes. [pmid: 9495666].
3986 Schwandner O, Schiedeck TH, Bruch HP. Stoma creation for fecal diversion: is the laparoscopic technique appropriate?. Int J Colorectal Dis. 1998;13(56):251-5. Case-series. [pmid: 9870171].
3987 Schwartz SL, Kennelly MJ, McGuire EJ, et al. Incontinent ileo-vesicostomy urinary diversion in the treatment of lower urinary tract dysfunction. J Urol. Jul. 1994;152(1):99-102. case-series. [pmid: 8201699].
3988 Scott AD, Henry MM, Phillips RK. Clinical assessment and anorectal manometry before postanal repair: failure to predict outcome. Br J Surg. Jun. 1990;77(6):628-9. Case-series. [pmid: 2383727].
3989 Scott D. Continence. Bangladeshi venture. Nurs Times. Oct 20–26. 1999;95(42):76-9. Comment. [pmid: 10788896].
3990 Scotti RJ, Garely AD, Greston WM, et al. Paravaginal repair of lateral vaginal wall defects by fixation to the ischial periosteum and obturator membrane. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1436-45. Case-series. [pmid: 9855578].
3991 Seaman EK, Benson MC. Improved continence with tubularized bladder neck reconstruction following radical retropubic prostatectomy. Urology. Apr. 1996;47(4):532-5. Case-series. [pmid: 8638363].
3992 Seccia M, Banti P, Zocco G, et al. Restoration of fecal continence with chronic electrostimulation of gracilis muscle 17 years after a Pickrell's operation. Int J Colorectal Dis. Nov. 2001;16(6):391-4. Case- Reports. [pmid: 11760901].
3993 Seccia M, Lippolis PV, Menconi C. Applied electrophysiology of transposed muscle stimulation: practical considerations and surgical experience on graciloplasty for faecal incontinence. Acta Biomed Ateneo Parmense. 2003;74(Suppl 2):84-8. Case-series.
3994 Seccia M, Menconi C, Balestri R, et al. Study protocols and functional results in 86 electrostimulated graciloplasties. Dis Colon Rectum. Sep. 1994;37(9):897-904. Case-series. [pmid: 8076489].
3995 Secil M, Goktay AY, Dicle O, et al. Bilateral epididymal Candida abscesses: sonographic findings and sonographically guided fine-needle aspiration. J Clin Ultrasound. Oct. 1998;26(8):413-5. Case Reports. [pmid: 9783250].
3996 Sedgwick DM, Howard GC, Ferguson A. Pathogenesis of acute radiation injury to the rectum. A prospective study in patients. Int J Colorectal Dis. Apr. 1994;9(1):23-30. Case-series. [pmid: 8027619].
3997 Seidel GK, Millis SR, Lichtenberg PA, et al. Predicting bowel and bladder continence from cognitive status in geriatric rehabilitation patients. Arch Phys Med Rehabil. May. 1994;75(5):590-3. Not eligible exposure. [pmid: 8185455].
3998 Seiler WO, Stahelin HB, Hefti U. Desmopressin reduces night urine volume in geriatric patients: implication for treatment of the nocturnal incontinence. Clin Investig. Jul. 1992;70(7):619. Comment.
3999 Seim A, Eriksen BC, Hunskaar S. A study of female urinary incontinence in general practice. Demography, medical history, and clinical findings. Scand J Urol Nephrol. Dec. 1996;30(6):465-71. Not eligible target population. [pmid: 9008027].
4000 Seim A, Hermstad R, Hunskaar S. Management in general practice significantly reduced psychosocial consequences of female urinary incontinence. Qual Life Res. Apr. 1997;6(3):257-64. Not eligible outcomes. [pmid: 9226983].
4001 Sekido N, Hinotsu S, Kawai K, et al. How many uncomplicated male and female overactive bladder patients reveal detrusor overactivity during urodynamic study?. Int J Urol. Oct. 2006;13(10):1276-9. Not eligible target population. [pmid: 17010004].
4002 Sekido N, Kawai K, Akaza H. Lower urinary tract dysfunction as persistent complication of radical hysterectomy. Int J Urol. May. 1997;4(3):259-64. Case-series. [pmid: 9255663].
4003 Selcuki M, Vatansever S, Inan S, et al. Is a filum terminale with a normal appearance really normal?. Childs Nerv Syst. Jan. 2003;19(1):3-10. Not eligible outcomes. [pmid: 12541079].
4004 Selli C, De Antoni P, Moro U, et al. Role of bladder neck preservation in urinary continence following radical retropubic prostatectomy. Scand J Urol Nephrol. 2004;38(1):32-7. Case-series. [pmid: 15204424].
4005 Sen I, Onaran M, Aksakal N, et al. The impact of urinary incontinence on female sexual function. Adv Ther. Nov–Dec. 2006;23(6):999-1008. Not eligible outcomes. [pmid: 17276967].
4006 Senapati A, Phillips RK. The trephine colostomy: a permanent left iliac fossa end colostomy without recourse to laparotomy. Ann R Coll Surg Engl. Sep. 1991;73(5):305-6. Case-series. [pmid: 1929133]. [pmcid: 2499487].
4007 Sendag F, Vidinli H, Kazandi M, et al. Role of perineal sonography in the evaluation of patients with stress urinary incontinence. Aust N Z J Obstet Gynaecol. Feb. 2003;43(1):54-7. Not eligible outcomes. [pmid: 12755349].
4008 Sengstaken EA, King SA. Chronic schizophrenia or meningioma?. J Am Board Fam Pract. Jan–Feb. 1994;7(1):71-3. Not eligible exposure. [pmid: 8135140].
4009 Sentovich SM. Fibrin glue for anal fistulas: long-term results. Dis Colon Rectum. Apr. 2003;46(4):498-502. Case-series. [pmid: 12682544].
4010 Sentovich SM, Blatchford GJ, Rivela LJ, et al. Diagnosing anal sphincter injury with transanal ultrasound and manometry. Dis Colon Rectum. Dec. 1997;40(12):1430-4. Not eligible exposure. [pmid: 9407980].
4011 Sentovich SM, Rivela LJ, Blatchford GJ, et al. Patterns of male fecal incontinence. Dis Colon Rectum. Mar. 1995;38(3):281-5. Not eligible outcomes. [pmid: 7882793].
4012 Sentovich SM, Wong WD, Blatchford GJ. Accuracy and reliability of transanal ultrasound for anterior anal sphincter injury. Dis Colon Rectum. Aug. 1998;41(8):1000-4. Not eligible outcomes. [pmid: 9715156].
4013 Seoud M, Abbas J, Kaspar H, et al. Long-term survival following aggressive surgery and radiotherapy for pelvic fibromatosis. Int J Gynecol Cancer. Nov–Dec. 2005;15(6):1112-4. Case- Reports. [pmid: 16343190].
4014 Seow C, Phillips RK. Insights gained from the management of problematical anal fistulae at St. Mark's Hospital, 1984-88. Br J Surg. May. 1991;78(5):539-41. Not eligible exposure. [pmid: 2059800].
4015 Seow-Choen F, Leong AF, Goh HS. Results of a policy of selective immediate fistulotomy for primary anal abscess. Aust N Z J Surg. Jun. 1993;63(6):485-9. Not eligible exposure. [pmid: 8498920].
4016 Seracchioli R, Hourcabie JA, Vianello F, et al. Laparoscopic treatment of pelvic floor defects in women of reproductive age. J Am Assoc Gynecol Laparosc. Aug. 2004;11(3):332-5. Case-series. [pmid: 15559343].
4017 Serel TA, Gungor M. Urodynamic evaluation after endoscopic modified bladder neck suspension. Urol Int. 1999;62(1):17-20. Not eligible exposure. [pmid: 10436425].
4018 Serels S, Stein M. Prospective study comparing hyoscyamine, doxazosin, and combination therapy for the treatment of urgency and frequency in women. Neurourol Urodyn. 1998;17(1):31-6. Not eligible target population. [pmid: 9453690].
4019 Serels SR, Rackley RR, Appell RA. In situ slings with concurrent cystocele repair. Tech Urol. Sep. 1999;5(3):129-32. Case-series. [pmid: 10527254].
4020 Serels SR, Rackley RR, Appell RA. Surgical treatment for stress urinary incontinence associated with valsalva induced detrusor instability. J Urol. Mar. 2000;163(3):884-7. Case-series. [pmid: 10688000].
4021 Serra DB, Affrime MB, Bedigian MP, et al. QT and QTc interval with standard and supratherapeutic doses of darifenacin, a muscarinic M3 selective receptor antagonist for the treatment of overactive bladder. J Clin Pharmacol. Sep. 2005;45(9):1038-47. Not eligible exposure. [pmid: 16100298].
4022 Sertcelik N, Sagnak L, Imamoglu A, et al. The use of self-expanding metallic urethral stents in the treatment of recurrent bulbar urethral strictures: long-term results. BJU Int. Oct. 2000;86(6):686-9. Case-series. [pmid: 11069377].
4023 Servoll E, Halvorsen OJ, Haukaas S, et al. Radical retropubic prostatectomy: our experience with the first 54 patients. Scand J Urol Nephrol. 1992;26(3):231-4. Case-series. [pmid: 1439599].
4024 Setti Carraro P, Kamm MA, Nicholls RJ. Long-term results of postanal repair for neurogenic faecal incontinence. Br J Surg. Jan. 1994;81(1):140-4. Case-series. [pmid: 8313093].
4025 Setti Carraro P, Nicholls RJ. Postanal repair for faecal incontinence persisting after rectopexy. Br J Surg. Feb. 1994;81(2):305-7. Case-series. [pmid: 8156370].
4026 Setti-Carraro P, Ritchie JK, Wilkinson KH, et al. The first 10 years' experience of restorative proctocolectomy for ulcerative colitis. Gut. Aug. 1994;35(8):1070-5. Not eligible outcomes. [pmid: 7926908]. [pmcid: 1375057].
4027 Sevestre S, Ciofu C, Deval B, et al. Results of the tension-free vaginal tape technique in the elderly. Eur Urol. Jul. 2003;44(1):128-31. Case-series. [pmid: 12814688].
4028 Sezai D, Demirbas S, Akin L, et al. The impact of laparoscopic resection rectopexy in patients with total rectal prolapse. Mil Med. Sep. 2005;170(9):743-7. Case-series. [pmid: 16261977].
4029 Shader RI, Oesterheld JR. Case 7: the addled nonagenarian. J Clin Psychopharmacol. Oct. 1995;15(5):378. Case- Reports. [pmid: 8830074].
4030 Shafik A. Detrusor-rectal neck dyssynergia syndrome. A new syndrome with report of nine cases. Int Surg. Oct–Dec. 1991;76(4):241-4. Case-series. [pmid: 1778722].
4031 Shafik A. Dilatation and closing anal reflexes. Description and clinical significance of new reflexes: preliminary report. Acta Anat (Basel). 1991;142(4):293-8. Not eligible outcomes. [pmid: 1801520].
4032 Shafik A. Uninhibited anal sphincter relaxation syndrome. A new syndrome with report of four cases. J Clin Gastroenterol. Jul. 1992;15(1):29-32. Case- Reports. [pmid: 1500658].
4033 Shafik A. Polytetrafluoroethylene injection for the treatment of partial fecal incontinence. Int Surg. Apr–Jun. 1993;78(2):159-61. Case-series. [pmid: 8354617].
4034 Shafik A. Basic testing of an artificial pacemaker in the normal and incontinent anorectum. Digestion. 1993;54(2):112-7. Not eligible exposure. [pmid: 8319839].
4035 Shafik A. Anorectal tightening reflex: role in fecal incontinence. Eur Surg Res. 1993;25(6):399-405. Question 4. [pmid: 8276040].
4036 Shafik A. Perianal injection of autologous fat for treatment of sphincteric incontinence. Dis Colon Rectum. Jun. 1995;38(6):583-7. Case-series. [pmid: 7774467].
4037 Shafik A. Electrovesicogram in stress urinary incontinence: a preliminary study. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(4):203-7. Not eligible outcomes. [pmid: 10895805].
4038 Shafik A. Pudendal canal decompression for the treatment of fecal incontinence in complete rectal prolapse. Am Surg. May. 1996;62(5):339-43. Case-series. [pmid: 8615558].
4039 Shafik A. Endoscopic pudendal canal decompression for the treatment of fecal incontinence due to pudendal canal syndrome. J Laparoendosc Adv Surg Tech A. Aug. 1997;7(4):227-34. Case-series. [pmid: 9448117].
4040 Shafik A. Role of pudendal canal syndrome in the etiology of fecal incontinence in rectal prolapse. Digestion. 1997;58(5):489-93. Not eligible outcomes. [pmid: 9383642].
4041 Shafik A. Pudendal canal syndrome as a cause of vulvodynia and its treatment by pudendal nerve decompression. Eur J Obstet Gynecol Reprod Biol. Oct. 1998;80(2):215-20. Case-series. [pmid: 9846672].
4042 Shafik A. Suppression of uninhibited rectal detrusor by functional magnetic stimulation of sacral root. J Spinal Cord Med. Spring. 2000;23(1):45-50. Case-series. [pmid: 10752874].
4043 Shafik A. Injured external anal sphincter in erectile dysfunction. Andrologia. Jan. 2001;33(1):35-41. Not eligible outcomes. [pmid: 11167517].
4044 Shafik A. Magnetic pudendal neurostimulation: a novel method for measuring pudendal nerve terminal motor latency. Clin Neurophysiol. Jun. 2001;112(6):1049-52. Not eligible outcomes. [pmid: 11377264].
4045 Shafik A. Stress urinary incontinence: new concept of pathogenesis and treatment by pudendal canal decompression. Adv Exp Med Biol. 2003;539(Pt A):415-40. Case-series. [pmid: 15088920].
4046 Shafik A, Ahmed A. The “uninhibited rectum”: a cause of fecal incontinence. J Spinal Cord Med. Fall. 2001;24(3):159-63. Not eligible outcomes. [pmid: 11585235].
4047 Shafik A, Ahmed I, El Sibai O, et al. Study of the rectal electric activity of the uninhibited rectal detrusor (overactive rectum): a new concept of pathogenesis. J Spinal Cord Med. 2005;28(1):64-8. Not eligible outcomes. [pmid: 15832906].
4048 Shafik A, Ahmed I, El-Sibai O, et al. Percutaneous peripheral neuromodulation in the treatment of fecal incontinence. Eur Surg Res. Mar–Apr. 2003;35(2):103-7. Not eligible target population. [pmid: 12679620].
4049 Shafik A, Doss S, Ali YA, et al. Transverse folds of rectum: anatomic study and clinical implications. Clin Anat. May. 2001;14(3):196-203. Not eligible outcomes. [pmid: 11301467].
4050 Shafik A, El Sibai O, Shafik IA, et al. Stress, urge, and mixed types of partial fecal incontinence: pathogenesis, clinical presentation, and treatment. Am Surg. Jan. 2007;73(1):6-9. Not eligible outcomes. [pmid: 17249447].
4051 Shafik A, El-Sibai O. The anocavernosal erectile dysfunction syndrome. II Anal fissure and erectile dysfunction. Int J Impot Res. Oct. 2000;12(5):279-83. Not eligible outcomes. [pmid: 11424966].
4052 Shafik A, El-Sibai O. Study of the levator ani muscle in the multipara: role of levator dysfunction in defecation disorders. J Obstet Gynaecol. Mar. 2002;22(2):187-92. Not eligible exposure. [pmid: 12521706].
4053 Shafik A, El-Sibai O, Shafik I, et al. Effect of micturition on the external anal sphincter: identification of the urethro-anal reflex. J Spinal Cord Med. 2005;28(5):421-5. Not eligible target population. [pmid: 16869089]. [pmcid: 1808274].
4054 Shafik A, Shafik IA. Overactive bladder inhibition in response to pelvic floor muscle exercises. World J Urol. May. 2003;20(6):374-7. Not eligible outcomes. [pmid: 12682771].
4055 Shah DK, Paul EM, Rastinehad AR, et al. Short-term outcome analysis of total pelvic reconstruction with mesh: the vaginal approach. J Urol. Jan. 2004;171(1):261-3. Case-series. [pmid: 14665889].
4056 Shah M, Moogerfeld MS, Ahmed J, et al. Metastatic cervical cancer with unusual presentation: a case report. Conn Med. Sep. 2001;65(9):523-5. Case report. [pmid: 11678057].
4057 Shah PN, Maly RC, Frank JC, et al. Managing geriatric syndromes: what geriatric assessment teams recommend, what primary care physicians implement, what patients adhere to. J Am Geriatr Soc. Apr. 1997;45(4):413-9. Not eligible outcomes. [pmid: 9100708].
4058 Shah SM, Bukkapatnam R, Rodriguez LV. Impact of vaginal surgery for stress urinary incontinence on female sexual function: is the use of polypropylene mesh detrimental?. Urology. Feb. 2005;65(2):270-4. Not eligible outcomes. [pmid: 15708036].
4059 Shaker DA, De Boer F. Performance of the tension free vaginal tape procedure when combined with sacrospinous fixation for apical prolapse. J Obstet Gynaecol. Oct. 2006;26(7):663-6. Case-series. [pmid: 17071435].
4060 Shakhatreh FM. Epidemiology of urinary incontinence in Jordanian women. Saudi Med J. May. 2005;26(5):830-5. Not eligible level of evidence. [pmid: 15951878].
4061 Shamim SM, Hameed K. Surgically treated rectal prolapse: experience at a teaching hospital. J Pak Med Assoc. Jun. 2005;55(6):247-50. Case-series. [pmid: 16045095].
4062 Shandera KC. Diagnosis and management of female urinary incontinence. Hawaii Med J. Dec. 1998;57(12):746-8. Comment. [pmid: 9893390].
4063 Shandling B, Chait PG, Richards HF. Percutaneous cecostomy: a new technique in the management of fecal incontinence. J Pediatr Surg. Apr. 1996;31(4):534-7. Not eligible target population. [pmid: 8801307].
4064 Shankar KR, Losty PD, Kenny SE, et al. Functional results following the antegrade continence enema procedure. Br J Surg. Jul. 1998;85(7):980-2. Not eligible target population. [pmid: 9692578].
4065 Sharma B, Oligbo N. Delayed vaginal erosion of the tape—a rare complication with TVT. J Obstet Gynaecol. Jan. 2004;24(1):96-8. Not eligible exposure. [pmid: 14676000].
4066 Sharp HT, Doucette RC, Norton PA. Dyspareunia and recurrent stress urinary incontinence after laparoscopic colposuspension with mesh and staples. A case report. J Reprod Med. Nov. 2000;45(11):947-9. Case Reports. [pmid: 11127111].
4067 Shatari T, Fujita M, Kodaira S. Dynamic graciloplasty resulting fecal continence without electrical stimulation: report of a case. Surg Today. 2004;34(5):463-5. Case- Reports. [pmid: 15108091].
4068 Shatari T, Hayes J, Pretlove S, et al. Importance of evacuatory disturbance in evaluation of faecal incontinence after third degree obstetric tear. Colorectal Dis. Jan. 2005;7(1):18-21. Case-series. [pmid: 15606579].
4069 Shaul DB, Harrison EA, Muenchow SK. Avoidance of leakage and strictures when creating an invisible conduit for antegrade colonic enemas. J Pediatr Surg. Dec. 2002;37(12):1768-71. Case-series. [pmid: 12483653].
4070 Shaw C, McColl E, Bond S. Functional abilities and continence: the use of proxy respondents in research involving older people. Qual Life Res. 2000;9(10):1117-26. Not eligible outcomes. [pmid: 11401044].
4071 Shaw F. Continence—it's never too late. Nurs Times 1998 Feb 11–17; 94(6):68–70, 2. Case Reports
4072 Shaw M, Birch N. Facet joint cysts causing cauda equina compression. J Spinal Disord Tech. Oct. 2004;17(5):442-5. Not eligible exposure. [pmid: 15385886].
4073 Shaya MR, Willis BK, Nanda A. Diffuse back pain and urological symptoms: recognizing tethered cord syndrome early. J La State Med Soc. Jan–Feb. 2005;157(1):39-41. Case report. [pmid: 15887667].
4074 Sheldon CA, Minevich E, Wacksman J, et al. Role of the antegrade continence enema in the management of the most debilitating childhood recto-urogenital anomalies. J Urol. Sep. 1997;158(3 Pt 2):1277-9. discussion 9–80. Not eligible target population. [pmid: 9258194].
4075 Sheldon R, Kiff ES, Clarke A, et al. Sacral nerve stimulation reduces corticoanal excitability in patients with faecal incontinence. Br J Surg. Nov. 2005;92(11):1423-31. Case-series. [pmid: 16044426].
4076 Shepherd BD, Merchant N, Fasig J, et al. Endoscopic ultrasound diagnosis of pelvic lipoma causing neurologic symptoms. Dig Dis Sci. Aug. 2006;51(8):1364-6. Not eligible exposure. [pmid: 16868819].
4077 Sherer DM, Abramowicz JS, Perillo AM, et al. Post cesarean delivery atonic bladder with overflow incontinence appearing sonographically as a large retrovesical hypoechoic mass. J Ultrasound Med. Jun. 1993;12(6):365-7. Case-reports. [pmid: 8515537].
4078 Sheriff MK, Foley S, McFarlane J, et al. Endoscopic correction of intractable stress incontinence with silicone micro-implants. Eur Urol. 1997;32(3):284-8. Case-series. [pmid: 9358214].
4079 Sheriff MK, Shah PJ, Fowler C, et al. Neuromodulation of detrusor hyper-reflexia by functional magnetic stimulation of the sacral roots. Br J Urol. Jul. 1996;78(1):39-46. Case-series. [pmid: 8795398].
4080 Sherman AM. An introduction to urinary incontinence. Orthop Nurs. Nov–Dec. 1993;12(6):27-30. Comment. [pmid: 8121707].
4081 Sherman AM, Shumaker SA, Kancler C, et al. Baseline health-related quality of life in postmenopausal women with coronary heart disease: the Estrogen Replacement and Atherosclerosis (ERA) trial. J Womens Health (Larchmt). May. 2003;12(4):351-62. Not eligible level of evidence. [pmid: 12804342].
4082 Sherman AM, Shumaker SA, Sharp P, et al. No effect of HRT on health-related quality of life in postmenopausal women with heart disease. Minerva Ginecol. Dec. 2003;55(6):511-7. Not eligible target population. [pmid: 14676740].
4083 Sherman FT. Functional assessment. Easy-to-use screening tools speed initial office work-up. Geriatrics. Aug. 2001;56(8):36-40. quiz 3. Not eligible exposure.
4084 Sherman S, Umlauf MG. Urinary incontinence in community dwelling elders. Urol Nurs. Dec. 1993;13(4):120-7. Question 1. [pmid: 8290999].
4085 Shetty SD, Kirkemo AK. Bilateral bone anchor vaginal vault suspension: an initial report of a new technique. Tech Urol. Spring. 1997;3(1):1-5. Case-series. [pmid: 9170217].
4086 Shih YC, Hartzema AG, Tolleson-Rinehart S. Labor costs associated with incontinence in long-term care facilities. Urology. Sep. 2003;62(3):442-6. Not eligible outcomes. [pmid: 12946743].
4087 Shimanouchi S, Kamei T, Hayashi M. Home care for the frail elderly based on urinary incontinence level. Public Health Nurs. Nov–Dec. 2000;17(6):468-73. Not eligible outcomes. [pmid: 11115145].
4088 Shinno Y, Koyanagi T, Kakizaki H, et al. Urinary control after radical transurethral resection of the prostate in male paraplegics: urodynamic evaluation of its effectiveness in relieving incontinence. Int J Urol. Mar. 1994;1(1):78-84. Case-series. [pmid: 7627842].
4089 Shinopulos NM, Dann JA, Smith JJ 3rd. Patient selection and education for use of the CapSure (Re/Stor) continence shield. Urol Nurs. Jun. 1999;19(2):135-40. Case-series. [pmid: 10633764].
4090 Shinopulos NM, Jacobson J. Relationship between health promotion lifestyle profiles and patient outcomes of biofeedback therapy for urinary incontinence. Urol Nurs. Dec. 1999;19(4):249-53. Case-series. [pmid: 10889768].
4091 Shiohama N, Shinomiya S, Nagaoka M. Clinical features of anterior bradyrhythmia. Clin Electroencephalogr. Oct. 1993;24(4):194-201. Not eligible exposure. [pmid: 8261643].
4092 Shiwach RS, Peris L. Treatment of major depression complicated by bilateral foot drop and double incontinence with ECT. J Ect. Dec. 2000;16(4):419-20. Case- Reports. [pmid: 11314881].
4093 Shobeiri SA, Chesson RR, Echols KT. Cystoscopic fistulography: a new technique for the diagnosis of vesicocervical fistula. Obstet Gynecol. Dec. 2001;98(6):1124-6. Case-reports. [pmid: 11755564].
4094 Shobeiri SA, Echols KT, Franco N. Sinus formation after insertion of a silicone-coated suburethral sling. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):356-7. Case Reports. [pmid: 14618316].
4095 Shobeiri SA, Nolan TE, Yordan-Jovet R, et al. Digital examination compared to trans-perineal ultrasound for the evaluation of anal sphincter repair. Int J Gynaecol Obstet. Jul. 2002;78(1):31-6. Not eligible outcomes. [pmid: 12113968].
4096 Shoukry MS, el-Salmy S. Urethral needle suspension for male urinary incontinence. Scand J Urol Nephrol. Jun. 1997;31(3):267-70. Case-series. [pmid: 9249891].
4097 Showalter PR, Zimmern PE, Roehrborn CG, et al. Standing cystourethrogram: an outcome measure after anti-incontinence procedures and cystocele repair in women. Urology. Jul. 2001;58(1):33-7. Not eligible outcomes.
4098 Sibbald B. Unique health needs of elderly women being ignored, symposium told. Cmaj. Nov 16. 1999;161(10):1309-10. Comment. [pmid: 10584100]. [pmcid: 1230804].
4099 Siddiqui AA, Shah AA. Chance-type flexion-distraction fracture of lumbar spine. J Coll Physicians Surg Pak. Jun. 2004;14(6):372-3. Case- Reports. [pmid: 15233897].
4100 Sidi AA, Becher EF, Reddy PK, et al. Augmentation enterocystoplasty for the management of voiding dysfunction in spinal cord injury patients. J Urol. Jan. 1990;143(1):83-5. Case-series. [pmid: 2294270].
4101 Siegel SW, Catanzaro F, Dijkema HE, et al. Long-term results of a multicenter study on sacral nerve stimulation for treatment of urinary urge incontinence, urgency-frequency, and retention. Urology. Dec 4. 2000;56(6 Suppl 1):87-91. Not eligible target population.
4102 Siegel SW, Richardson DA, Miller KL, et al. Pelvic floor electrical stimulation for the treatment of urge and mixed urinary incontinence in women. Urology. Dec. 1997;50(6):934-40. Not eligible outcomes. [pmid: 9426726].
4103 Siegelman ES, Banner MP, Ramchandani P, et al. Multicoil MR imaging of symptomatic female urethral and periurethral disease. Radiographics. Mar–Apr. 1997;17(2):349-65. Not eligible exposure. [pmid: 9084077].
4104 Siegler EL, Reidenberg M. Treatment of urinary incontinence with anticholinergics in patients taking cholinesterase inhibitors for dementia. Clin Pharmacol Ther. May. 2004;75(5):484-8. Case- Reports. [pmid: 15116061].
4105 Siltberg H, Larsson G, Victor A. Reproducibility of a new method to determine cough-induced leak-point pressure in women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(1):13-9. Case-series. [pmid: 8798081].
4106 Siltberg H, Larsson G, Victor A. Frequency/volume chart: the basic tool for investigating urinary symptoms. Acta Obstet Gynecol Scand Suppl. 1997;166:24-7. [pmid: 9253374].
4107 Siltberg H, Larsson G, Victor A. Cough-induced leak-point pressure—a valid measure for assessing treatment in women with stress incontinence. Acta Obstet Gynecol Scand. Nov. 1998;77(10):1000-7. Not eligible target population. [pmid: 9849845].
4108 Silva C, Silva J, Ribeiro MJ, et al. Urodynamic effect of intravesical resiniferatoxin in patients with neurogenic detrusor overactivity of spinal origin: results of a double-blind randomized placebo-controlled trial. Eur Urol. Oct. 2005;48(4):650-5. Not eligible exposure. [pmid: 15961217].
4109 Silva WA, Pauls RN, Segal JL, et al. Uterosacral ligament vault suspension: five-year outcomes. Obstet Gynecol. Aug. 2006;108(2):255-63. Case-series. [pmid: 16880293].
4110 Silverman M, McDowell BJ, Musa D, et al. To treat or not to treat: issues in decisions not to treat older persons with cognitive impairment, depression, and incontinence. J Am Geriatr Soc. Sep. 1997;45(9):1094-101. Not eligible outcomes. [pmid: 9288017].
4111 Silvis R, Gooszen HG, Kahraman T, et al. Novel approach to combined defaecation and micturition disorders with rectovaginovesicopexy. Br J Surg. Jun. 1998;85(6):813-7. Case-series. [pmid: 9667715].
4112 Silvis R, Gooszen HG, van Essen A, et al. Abdominal rectovaginopexy: modified technique to treat constipation. Dis Colon Rectum. Jan. 1999;42(1):82-8. Case-series. [pmid: 10211525].
4113 Silvis R, van Eekelen JW, Delemarre JB, et al. Endosonography of the anal sphincter after ileal pouch-anal anastomosis. Relation with anal manometry and fecal continence. Dis Colon Rectum. Apr. 1995;38(4):383-8. Not eligible outcomes. [pmid: 7720445].
4114 Simeonova Z, Bengtsson C. Prevalence of urinary incontinence among women at a Swedish primary health care centre. Scand J Prim Health Care. Dec. 1990;8(4):203-6. Not eligible level of evidence. [pmid: 2284519].
4115 Simforoosh N, Norbala MH, Danesh A, et al. Proper use of gastrointestinal tract to achieve continent urinary diversion in 73 patients. J Urol (Paris). 1992;98(4):206-9. Case-series. [pmid: 1297666].
4116 Simmang C, Birnbaum EH, Kodner IJ, et al. Anal sphincter reconstruction in the elderly: does advancing age affect outcome?. Dis Colon Rectum. Nov. 1994;37(11):1065-9. Case-series. [pmid: 7956570].
4117 Simmons SF, Ouslander JG. Resident and family satisfaction with incontinence and mobility care: sensitivity to intervention effects?. Gerontologist. Jun. 2005;45(3):318-26. Not eligible outcomes. [pmid: 15933272].
4118 Simonis LA, Borovets S, Van Driel MF, et al. Erectile dysfunction due to a ‘hidden’ penis after pelvic trauma. Int J Impot Res. Feb. 1999;11(1):53-5. Case Reports. [pmid: 10098955].
4119 Simons AM, Dowell CJ, Bryant CM, et al. Use of the Dowell Bryant Incontinence Cost Index as a post-treatment outcome measure after non-surgical therapy. Neurourol Urodyn. 2001;20(1):85-93. Case-series. [pmid: 11135385].
4120 Simons AM, Yoong WC, Buckland S, et al. Inadequate repeatability of the one-hour pad test: the need for a new incontinence outcome measure. Bjog. Mar. 2001;108(3):315-9. Case-series. [pmid: 11281474].
4121 Simor AE, Yake SL, Tsimidis K. Infection due to Clostridium difficile among elderly residents of a long-term-care facility. Clin Infect Dis. Oct. 1993;17(4):672-8. Not eligible outcomes. [pmid: 7903557].
4122 Simpson RR, Kennedy ML, Nguyen MH, et al. Anal manometry: a comparison of techniques. Dis Colon Rectum. Jul. 2006;49(7):1033-8. Not eligible outcomes. [pmid: 16729220].
4123 Simsiman AJ, Luber KM, Menefee SA. Vaginal paravaginal repair with porcine dermal reinforcement: correction of advanced anterior vaginal prolapse. Am J Obstet Gynecol. Dec. 2006;195(6):1832-6. Not eligible outcomes. [pmid: 17010297].
4124 Singh G, Thomas DG. Artificial urinary sphincter in patients with neurogenic bladder dysfunction. Br J Urol. Feb. 1996;77(2):252-5. Case-series. [pmid: 8800894].
4125 Singh G, Thomas DG. Artificial urinary sphincter for post-prostatectomy incontinence. Br J Urol. Feb. 1996;77(2):248-51. Case-series. [pmid: 8800893].
4126 Singh G, Thomas DG. Bowel problems after enterocystoplasty. Br J Urol. Mar. 1997;79(3):328-32. Case-series. [pmid: 9117209].
4127 Singh G, Wilkinson JM, Thomas DG. Supravesical diversion for incontinence: a long-term follow-up. Br J Urol. Mar. 1997;79(3):348-53. Case-series. [pmid: 9117212].
4128 Singh H, Karakiewicz P, Shariat SF, et al. Impact of unilateral interposition sural nerve grafting on recovery of urinary function after radical prostatectomy. Urology. Jun. 2004;63(6):1122-7. Case-series. [pmid: 15183964].
4129 Singh K, Cortes E, Reid WM. Evaluation of the fascial technique for surgical repair of isolated posterior vaginal wall prolapse. Obstet Gynecol. Feb. 2003;101(2):320-4. Not eligible exposure. [pmid: 12576256].
4130 Singh M, Sharma A, Duthie G, et al. Early results of a rotation flap to treat chronic anal fissures. Asian J Surg. Jul. 2005;28(3):189-91. Not eligible exposure. [pmid: 16024313].
4131 Singh R, Hunter J, Philip A, et al. Predicting those who will walk after rehabilitation in a specialist stroke unit. Clin Rehabil. Feb. 2006;20(2):149-52. Not eligible level of evidence. [pmid: 16541935].
4132 Sinha D, Nallaswamy V, Arunkalaivanan AS. Value of leak point pressure study in women with incontinence. J Urol. Jul. 2006;176(1):186-8. discussion 8. Not eligible outcomes. [pmid: 16753397].
4133 Siow A, Morris AR, Lam A. Laparoscopic treatment of tension free vaginal tape erosion. Aust N Z J Obstet Gynaecol. Aug. 2005;45(4):333. Case Reports. [pmid: 16029305].
4134 Siproudhis L, Bellissant E, Juguet F, et al. Perception of and adaptation to rectal isobaric distension in patients with faecal incontinence. Gut. May. 1999;44(5):687-92. Not eligible outcomes. [pmid: 10205206]. [pmcid: 1727504].
4135 Siproudhis L, Bellissant E, Juguet F, et al. Rectal adaptation to distension in patients with overt rectal prolapse. Br J Surg. Nov. 1998;85(11):1527-32. Not eligible outcomes. [pmid: 9823917].
4136 Siproudhis L, Bellissant E, Pagenault M, et al. Fecal incontinence with normal anal canal pressures: where is the pitfall?. Am J Gastroenterol. Jun. 1999;94(6):1556-63. No associative hypothesis tested. [pmid: 10364025].
4137 Siproudhis L, Dautreme S, Ropert A, et al. Dyschezia and rectocele—a marriage of convenience? Physiologic evaluation of the rectocele in a group of 52 women complaining of difficulty in evacuation. Dis Colon Rectum. Nov. 1993;36(11):1030-6. Not eligible outcomes. [pmid: 8223055].
4138 Siproudhis L, Pigot F, Godeberge P, et al. Defecation disorders: a French population survey. Dis Colon Rectum. Feb. 2006;49(2):219-27. Not eligible level of evidence. [pmid: 16362804].
4139 Siracusano S, Bertolotto M, Silvestre G, et al. The feasibility of urethral color ultrasound imaging in the diagnosis of female intrinsic sphincter deficiency: preliminary results. Spinal Cord. Apr. 2002;40(4):192-5. Not eligible outcomes. [pmid: 11965558].
4140 Siracusano S, Pregazzi R, d'Aloia G, et al. Prevalence of urinary incontinence in young and middle-aged women in an Italian urban area. Eur J Obstet Gynecol Reprod Biol. Apr 25. 2003;107(2):201-4. Not eligible level of evidence. [pmid: 12648869].
4141 Sirls LT, Foote JE, Kaufman JM, et al. Long-term results of the FemSoft urethral insert for the management of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):88-95. discussion Case-series. [pmid: 12054188].
4142 Sirls LT, Keoleian CM, Korman HJ, et al. The effect of study methodology on reported success rates of the modified Pereyra bladder neck suspension. J Urol. Nov. 1995;154(5):1732-5. Not eligible exposure. [pmid: 7563334].
4143 Sitoh YY, Lau TC, Zochling J, et al. Determinants of health-related quality of life in institutionalised older persons in northern Sydney. Intern Med J. Feb. 2005;35(2):131-4. Not eligible outcomes. [pmid: 15705146].
4144 Sitoh YY, Sitoh YY, Sahadevan S. Clinical significance of cerebral white matter lesions in older Asians with suspected dementia. Age Ageing. Jan. 2004;33(1):67-71. Not eligible outcomes. [pmid: 14695866].
4145 Siu AL, Beers MH, Morgenstern H. The geriatric “medical and public health” imperative revisited. J Am Geriatr Soc. Jan. 1993;41(1):78-84. Review. [pmid: 8418128].
4146 Siu LS, Chang AM, Yip SK, et al. Compliance with a pelvic muscle exercise program as a causal predictor of urinary stress incontinence amongst Chinese women. Neurourol Urodyn. 2003;22(7):659-63. Not eligible outcomes. [pmid: 14595610].
4147 Skala C, Emons G, Krauss T, et al. Postoperative funneling after anti-incontinence surgery—a prognostic indicator?—Part 1: colposuspension. Neurourol Urodyn. 2004;23(7):636-42. Not eligible outcomes. [pmid: 15382191].
4148 Skeil D, Thorpe AC. Transcutaneous electrical nerve stimulation in the treatment of neurological patients with urinary symptoms. BJU Int. Dec. 2001;88(9):899-908. Case-series. [pmid: 11851611].
4149 Skelly J, Boblin-Cummings S. Promoting seniors' health—confronting the issue of incontinence. Can J Nurs Leadersh. Sep–Oct. 1999;12(3):13-7. Not eligible outcomes. [pmid: 11094934].
4150 Skilling PM, Petros P. Synergistic non-surgical management of pelvic floor dysfunction: second report. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):106-10. discussion 10. Case-series. [pmid: 15014937].
4151 Skinner MH, Kuan HY, Skerjanec A, et al. Effect of age on the pharmacokinetics of duloxetine in women. Br J Clin Pharmacol. Jan. 2004;57(1):54-61. Not eligible outcomes. [pmid: 14678340]. [pmcid: 1884424].
4152 Skoner MM. Self-management of urinary incontinence among women 31 to 50 years of age. Rehabil Nurs 1994 Nov–Dec; 19(6):339–43, 47. Not eligible outcomes
4153 Skoner MM, Haylor MJ. Managing incontinence: women's normalizing strategies. Health Care Women Int. Nov–Dec. 1993;14(6):549-60. Not eligible outcomes. [pmid: 8138472].
4154 Skoner MM, Thompson WD, Caron VA. Factors associated with risk of stress urinary incontinence in women. Nurs Res. Sep–Oct. 1994;43(5):301-6. Not eligible level of evidence. [pmid: 7937177].
4155 Skorupski P, Krol J, Starega J, et al. An alpha-1 chain of type I collagen Sp1-binding site polymorphism in women suffering from stress urinary incontinence. Am J Obstet Gynecol. Feb. 2006;194(2):346-50. Not eligible outcomes. [pmid: 16458627].
4156 Slack M, Tracey M, Hunsicker K, et al. Urethral retro-resistance pressure: a new clinical measure of urethral function. Neurourol Urodyn. 2004;23(7):656-61. Not eligible exposure. [pmid: 15382197].
4157 Sladden MJ, Hughes AM, Hirst GH, et al. A community study of lower urinary tract symptoms in older men in Sydney, Australia. Aust N Z J Surg. May. 2000;70(5):322-8. Not eligible outcomes. [pmid: 10830592].
4158 Slors FJ, van Zuijlen PP, van Dijk GJ. Sexual and bladder dysfunction after total mesorectal excision for benign diseases. Scand J Gastroenterol Suppl 2000; (232):48–51. Case-series
4159 Sloss EM, Solomon DH, Shekelle PG, et al. Selecting target conditions for quality of care improvement in vulnerable older adults. J Am Geriatr Soc. Apr. 2000;48(4):363-9. Secondary data analysis. [pmid: 10798460].
4160 Small KA, Wynne JM. Evaluating the pelvic floor in obstetric patients. Aust N Z J Obstet Gynaecol 1990 Feb; 30(1):41–4, 5. Case-series
4161 Smart RF. Polytef paste for urinary incontinence. Aust N Z J Surg. Sep. 1991;61(9):663-6. Case-series. [pmid: 1877933].
4162 Smeenk RM, Bex A, Verwaal VJ, et al. Pseudomyxoma peritonei and the urinary tract: involvement and treatment related complications. J Surg Oncol. Jan 1. 2006;93(1):20-3. Case-series. [pmid: 16353186].
4163 Smith A, Rovner E. Long-term chronic complications from Stamey endoscopic bladder neck suspension: a case series. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):290-4. Case Reports. [pmid: 15965575].
4164 Smith DA, Newman DK. Basic elements of biofeedback therapy for pelvic muscle rehabilitation. Urol Nurs. Sep. 1994;14(3):130-5. Comment. [pmid: 7732415].
4165 Smith DB, Boileau MA, Buan LD. A self-directed home biofeedback system for women with symptoms of stress, urge, and mixed incontinence. J Wound Ostomy Continence Nurs. Jul. 2000;27(4):240-6. Not eligible target population. [pmid: 10896750].
4166 Smith DB, Lekan-Rutledge D. Continence management and wound care for a patient in a residential facility. J Wound Ostomy Continence Nurs. May. 1997;24(3):172-8. Case Reports. [pmid: 9224026].
4167 Smith DN, Appell RA, Rackley RR, et al. Collagen injection therapy for post-prostatectomy incontinence. J Urol. Aug. 1998;160(2):364-7. Case-series. [pmid: 9679878].
4168 Smith DN, Appell RA, Winters JC, et al. Collagen injection therapy for female intrinsic sphincteric deficiency. J Urol. Apr. 1997;157(4):1275-8. Case-series. [pmid: 9120919].
4169 Smith DN, Fralick R, Appell RA. Incontinence after placement of a sphincter. Urology. Dec. 1997;50(6):974. Case Reports. [pmid: 9426734].
4170 Smith DS, Krygiel J, Nease RF Jr, et al. Patient preferences for outcomes associated with surgical management of prostate cancer. J Urol. May. 2002;167(5):2117-22. Not eligible outcomes. [pmid: 11956454].
4171 Smith LJ, Franchetti B, McCoull K, et al. A behavioural approach to retraining bowel function after long-standing constipation and faecal impaction in people with learning disabilities. Dev Med Child Neurol. Jan. 1994;36(1):41-9. Case Reports. [pmid: 8132113].
4172 Smith M. Stress factor. Nurs Stand. Mar 28–Apr 3. 2001;15(28):26. Comment.
4173 Smith M. Better continence management. Nurs Stand. Jan 31–Feb 6. 2001;15(20):26-7. Comment.
4174 Smith MD, Bohlman HH. Spondylolisthesis treated by a single-stage operation combining decompression with in situ posterolateral and anterior fusion. An analysis of eleven patients who had long-term follow-up. J Bone Joint Surg Am. Mar. 1990;72(3):415-21. Case-series. [pmid: 2312539].
4175 Smith MD, Russell A, Hodges PW. Disorders of breathing and continence have a stronger association with back pain than obesity and physical activity. Aust J Physiother. 2006;52(1):11-6. Not eligible outcomes. [pmid: 16515418].
4176 Smith P. Estrogens and the urogenital tract. Studies on steroid hormone receptors and a clinical study on a new estradiol-releasing vaginal ring. Acta Obstet Gynecol Scand Suppl. 1993;157:1-26. Case-series. [pmid: 8393609].
4177 Smith VC, Boone TB, Truong LD. Collagen polyp of the urinary tract: a report of two cases. Mod Pathol. Dec. 1999;12(12):1090-3. Case- Reports. [pmid: 10619259].
4178 Smith W. Initiative to advise shoppers on continence. Nurs Times. Sep 13–19. 1995;91(37):11-2. Comment. [pmid: 7567508].
4179 Snape J, Hulman G, Reddy PR, et al. Pneumatosis coli: an uncommon but treatable cause of faecal incontinence. Int J Clin Pract. Oct. 1998;52(7):501-3. Case- Reports. [pmid: 10622093].
4180 Snijders F, de Boer JB, Steenbergen B, et al. Impact of diarrhoea and faecal incontinence on the daily life of HIV-infected patients. AIDS Care. Oct. 1998;10(5):629-37. Case-series. [pmid: 9828959].
4181 Snodgrass W. A simplified Kropp procedure for incontinence. J Urol. Sep. 1997;158(3 Pt 2):1049-52. Case-series. [pmid: 9258140].
4182 Snooks SJ, Swash M, Mathers SE, et al. Effect of vaginal delivery on the pelvic floor: a 5-year follow-up. Br J Surg. Dec. 1990;77(12):1358-60. Case-series. [pmid: 2276018].
4183 Snyder M, Pearson V, Hanscom J, et al. Barriers to progress in urinary incontinence: achieving quality assessments. Geriatr Nurs. Mar–Apr. 1998;19(2):77-80. Not eligible outcomes. [pmid: 9611504].
4184 Sobrado CW, Kiss DR, Nahas SC, et al. Surgical treatment of rectal prolapse: experience and late results with 51 patients. Rev Hosp Clin Fac Med Sao Paulo. Aug. 2004;59(4):168-71. Not eligible outcomes. [pmid: 15361980].
4185 Soderberg MW, Falconer C, Bystrom B, et al. Young women with genital prolapse have a low collagen concentration. Acta Obstet Gynecol Scand. Dec. 2004;83(12):1193-8. Not eligible outcomes. [pmid: 15548155].
4186 Soergel TM, Shott S, Heit M. Poor surgical outcomes after fascia lata allograft slings. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(4):247-53. Not eligible exposure. [pmid: 11569653].
4187 Sohail S, Siddiqui KJ. Trans-vaginal sonographic evaluation of vesicovaginal fistula. J Pak Med Assoc. Jul. 2005;55(7):292-4. Not eligible outcomes. [pmid: 16108513].
4188 Sokol AI, Jelovsek JE, Walters MD, et al. Incidence and predictors of prolonged urinary retention after TVT with and without concurrent prolapse surgery. Am J Obstet Gynecol. May. 2005;192(5):1537-43. Not eligible target population. [pmid: 15902154].
4189 Sole-Balcells F, Villavicencio H, Ortiz A. Postsurgical management of the patient undergoing radical prostatectomy. Br J Urol. Nov. 1992;70(Suppl 1):43-9. Case-series.
4190 Solomon MJ. Fistulae and abscesses in symptomatic perianal Crohn's disease. Int J Colorectal Dis. 1996;11(5):222-6. Review. [pmid: 8951512].
4191 Solomon MJ, Rex J, Eyers AA, et al. Biofeedback for fecal incontinence using transanal ultrasonography: novel approach. Dis Colon Rectum. Jun. 2000;43(6):788-92. Not eligible outcomes. [pmid: 10859078].
4192 Soloway MS, Neulander E. Bladder-neck preservation during radical retropubic prostatectomy. Semin Urol Oncol. Feb. 2000;18(1):51-6. Question 2. [pmid: 10719932].
4193 Sommerfeld DK, von Arbin MH. Disability test 10 days after acute stroke to predict early discharge home in patients 65 years and older. Clin Rehabil. Oct. 2001;15(5):528-34. Not eligible outcomes. [pmid: 11594642].
4194 Sone J, Hishikawa N, Koike H, et al. Neuronal intranuclear hyaline inclusion disease showing motor-sensory and autonomic neuropathy. Neurology. Nov 22. 2005;65(10):1538-43. Not eligible exposure. [pmid: 16301479].
4195 Song JT, Rozanski TA, Belville WD. Stress leak point pressure: a simple and reproducible method utilizing a fiberoptic microtransducer. Urology. Jul. 1995;46(1):81-4. Case-series. [pmid: 7604481].
4196 Song YF, Zhang WJ, Song J, et al. Prevalence and risk factors of urinary incontinence in Fuzhou Chinese women. Chin Med J (Engl). Jun 5. 2005;118(11):887-92. Not eligible level of evidence. [pmid: 15978188].
4197 Sonnino RE, Reinberg O, Bensoussan AL, et al. Gracilis muscle transposition for anal incontinence in children: long-term follow-up. J Pediatr Surg. Oct. 1991;26(10):1219-23. Not eligible target population. [pmid: 1779332].
4198 Sood AK, Nygaard I, Shahin MS, et al. Anorectal dysfunction after surgical treatment for cervical cancer. J Am Coll Surg. Oct. 2002;195(4):513-9. Case-series. [pmid: 12375757].
4199 Soon PS, Lynch W, Schwartz P. Breast cancer presenting initially with urinary incontinence: a case of bladder metastasis from breast cancer. Breast. Feb. 2004;13(1):69-71. Case report. [pmid: 14759720].
4200 Sorbye LW, Finne-Soveri H, Ljunggren G, et al. Indwelling catheter use in home care: elderly, aged 65+, in 11 different countries in Europe. Age Ageing. Jul. 2005;34(4):377-81. Not eligible target population. [pmid: 15901577].
4201 Sorensen M, Lorentzen M, Petersen J, et al. Anorectal dysfunction in patients with urologic disturbance due to multiple sclerosis. Dis Colon Rectum. Feb. 1991;34(2):136-9. Case-series. [pmid: 1993411].
4202 Sorensen M, Tetzschner T, Rasmussen OO, et al. Sphincter rupture in childbirth. Br J Surg. Mar. 1993;80(3):392-4. Case-series. [pmid: 8472162].
4203 Sorensen M, Tetzschner T, Rasmussen OO, et al. Relation between electromyography and anal manometry of the external anal sphincter. Gut. Sep. 1991;32(9):1031-4. Not eligible level of evidence. [pmid: 1916486]. [pmcid: 1379045].
4204 Sorensen M, Tetzschner T, Rasmussen OO, et al. Viscous fluid retention: a new method for evaluating anorectal function. Dis Colon Rectum. Apr. 1992;35(4):357-61. Not eligible outcomes. [pmid: 1582358].
4205 Soriano D, Lemoine A, Laplace C, et al. Results of recto-vaginal fistula repair: retrospective analysis of 48 cases. Eur J Obstet Gynecol Reprod Biol. May. 2001;96(1):75-9. Case-series. [pmid: 11311765].
4206 Sorin V, Ron Y, Smetana S, et al. Fecal incontinence secondary to CAPD. Am J Kidney Dis. Jan. 2003;41(1):E2. Case- Reports. [pmid: 12500212].
4207 Sotomayor M, Bernal GF. Twelve-month results of nonsurgical radiofrequency energy micro-remodeling for stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):192-6. discussion 6. Not eligible target population. [pmid: 15378235].
4208 Soulie M, Cuvillier X, Benaissa A, et al. The tension-free transvaginal tape procedure in the treatment of female urinary stress incontinence: a French prospective multicentre study. Eur Urol. Jun. 2001;39(6):709-14. discussion 15. Case-series. [pmid: 11464062].
4209 Soulie M, Seguin P, Martel P, et al. A modified intussuscepted nipple in the Kock pouch urinary diversion: assessment of perioperative complications and functional results. BJU Int. Sep. 2002;90(4):397-402. Case-series. [pmid: 12175396].
4210 Sousa-Escandon A, Rodriguez Gomez JI, Uribarri Gonzalez C, et al. Externally readjustable sling for treatment of male stress urinary incontinence: points of technique and preliminary results. J Endourol. Feb. 2004;18(1):113-8. Case-series. [pmid: 15006064].
4211 Southern D, Henderson P. Setting standards. Tackling incontinence. Nurs Times. Mar 7–13. 1990;86(10):36-8. Comment. [pmid: 2315081].
4212 Soygur T, Safak M, Yesilli C, et al. Extraperitoneal laparoscopic bladder neck suspension using hernia mesh and tacker. Urology. Jul. 2000;56(1):121-4. Case-series. [pmid: 10869639].
4213 Speakman CT, Burnett SJ, Kamm MA, et al. Sphincter injury after anal dilatation demonstrated by anal endosonography. Br J Surg. Dec. 1991;78(12):1429-30. Case-series. [pmid: 1773315].
4214 Speakman CT, Hoyle CH, Kamm MA, et al. Adrenergic control of the internal anal sphincter is abnormal in patients with idiopathic faecal incontinence. Br J Surg. Dec. 1990;77(12):1342-4. Not eligible target population. [pmid: 2276013].
4215 Speakman CT, Hoyle CH, Kamm MA, et al. Decreased sensitivity of muscarinic but not 5-hydroxytryptamine receptors of the internal anal sphincter in neurogenic faecal incontinence. Br J Surg. Aug. 1992;79(8):829-32. Not eligible target population. [pmid: 1393486].
4216 Speakman CT, Hoyle CH, Kamm MA, et al. Neuropeptides in the internal anal sphincter in neurogenic faecal incontinence. Int J Colorectal Dis. Dec. 1993;8(4):201-5. Not eligible outcomes. [pmid: 8163893].
4217 Speakman CT, Hoyle CH, Kamm MA, et al. Abnormal internal anal sphincter fibrosis and elasticity in fecal incontinence. Dis Colon Rectum. Apr. 1995;38(4):407-10. Not eligible outcomes. [pmid: 7720450].
4218 Speakman CT, Hoyle CH, Kamm MM, et al. Abnormalities of innervation of internal anal sphincter in fecal incontinence. Dig Dis Sci. Nov. 1993;38(11):1961-9. Not eligible target population. [pmid: 8223067].
4219 Speakman CT, Kamm MA. Abnormal visceral autonomic innervation in neurogenic faecal incontinence. Gut. Feb. 1993;34(2):215-21. Not eligible outcomes. [pmid: 8432476]. [pmcid: 1373973].
4220 Speakman CT, Kamm MA, Swash M. Rectal sensory evoked potentials: an assessment of their clinical value. Int J Colorectal Dis. Mar. 1993;8(1):23-8. Case-series. [pmid: 8492039].
4221 Spector WD. Correlates of pressure sores in nursing homes: evidence from the National Medical Expenditure Survey. J Invest Dermatol. Jun. 1994;102(6):42S-5S. Not eligible outcomes. [pmid: 8006435].
4222 Speights SE, Moore RD, Miklos JR. Frequency of lower urinary tract injury at laparoscopic burch and paravaginal repair. J Am Assoc Gynecol Laparosc. Nov. 2000;7(4):515-8. Not eligible outcomes. [pmid: 11044503].
4223 Spence-Jones C, Kamm MA, Henry MM, et al. Bowel dysfunction: a pathogenic factor in uterovaginal prolapse and urinary stress incontinence. Br J Obstet Gynaecol. Feb. 1994;101(2):147-52. Not eligible level of evidence. [pmid: 8305390].
4224 Spinelli M, Malaguti S, Giardiello G, et al. A new minimally invasive procedure for pudendal nerve stimulation to treat neurogenic bladder: description of the method and preliminary data. Neurourol Urodyn. 2005;24(4):305-9. Not eligible target population. [pmid: 15977260].
4225 Spinelli M, Weil E, Ostardo E, et al. New tined lead electrode in sacral neuromodulation: experience from a multicentre European study. World J Urol. Jul. 2005;23(3):225-9. Not eligible target population. [pmid: 15988594].
4226 Spinosa JP, Dubuis PY. Suburethral sling inserted by the transobturator route in the treatment of female stress urinary incontinence: preliminary results in 117 cases. Eur J Obstet Gynecol Reprod Biol. Dec 1. 2005;123(2):212-7. Case-series. [pmid: 16024161].
4227 Srinivasan V, Blackford HN. Genuine stress incontinence induced by prazosin. Br J Urol. Oct. 1993;72(4):510. Case Reports. [pmid: 8261310].
4228 Srisupan V, Senaratana W, Picheansatian W, et al. Reduction of the incidence of pressure sores by an education program on nursing care. J Med Assoc Thai. Dec. 2005;88(Suppl 10):S166-70. Not eligible outcomes. [pmid: 16850664].
4229 St John W, Wallis M. Outcome evaluation of a multi-disciplinary community-based continence service for Australian women. Women Health. 2004;40(2):35-52. Case-series.
4230 St John W, Wallis M, James H, et al. Targeting community-dwelling urinary incontinence sufferers: a multi-disciplinary community based model for conservative continence services. Contemp Nurse. Oct. 2004;17(3):211-22. Review. [pmid: 15551672].
4231 Stach-Lempinen B, Hakala AL, Laippala P, et al. Severe depression determines quality of life in urinary incontinent women. Neurourol Urodyn. 2003;22(6):563-8. Not eligible level of evidence. [pmid: 12951664].
4232 Stach-Lempinen B, Sintonen H, Kujansuu E. The relationship between clinical parameters and health-related quality of life as measured by the 15D in incontinent women before and after treatment. Acta Obstet Gynecol Scand. Oct. 2004;83(10):983-8. Not eligible outcomes. [pmid: 15453899].
4233 Stainton MC, Strahle A, Fethney J. Leaking urine prior to pregnancy: a risk factor for postnatal incontinence. Aust N Z J Obstet Gynaecol. Aug. 2005;45(4):295-9. Not eligible level of evidence. [pmid: 16029295].
4234 Stanisic TH, Jennings CE, Miller JI. Polytetrafluoroethylene injection for post-prostatectomy incontinence: experience with 20 patients during 3 years. J Urol. Dec. 1991;146(6):1575-7. Case-series. [pmid: 1942344].
4235 Staniunas RJ, Keck JO, Counihan T, et al. State of the defunctionalized sphincter in patients undergoing ileoanal pouch anastomosis. Dis Colon Rectum. May. 1995;38(5):458-61. Case-series. [pmid: 7736874].
4236 Stansbury JP, Mathewson-Chapman M, Grant KE. Gender schema and prostate cancer: veterans' cultural model of masculinity. Med Anthropol. Apr–Jun. 2003;22(2):175-204. Not eligible outcomes. [pmid: 12745638].
4237 Stanton AL, Bernaards CA, Ganz PA. The BCPT symptom scales: a measure of physical symptoms for women diagnosed with or at risk for breast cancer. J Natl Cancer Inst. Mar 16. 2005;97(6):448-56. Not eligible exposure. [pmid: 15770009].
4238 Stanton SL. Cut and dry—urinary incontinence in the female. Trans Med Soc Lond. 1990;107:9-11. Comment. [pmid: 2152428].
4239 Starer P, Libow L. Cystometric evaluation of bladder dysfunction in elderly diabetic patients. Arch Intern Med. Apr. 1990;150(4):810-3. Case-series. [pmid: 2327841].
4240 Starer P, Libow LS. Persistence of detrusor hyperreflexia in a continent, institutionalized elderly patient with Parkinson's disease. N Y State J Med. Apr. 1991;91(4):166-7. Case- Reports. [pmid: 2047037].
4241 Starkman JS, Wolter CE, Scarpero HM, et al. Management of refractory urinary urge incontinence following urogynecological surgery with sacral neuromodulation. Neurourol Urodyn. 2007;26(1):29-35. discussion 6. Case-series. [pmid: 17083097].
4242 Starr CH. The numbers lie. Bus Health 2002 Spring; Spec No:4–7, 23. No associative hypothesis tested
4243 Starr CH. Eroding the quality of life. Bus Health 2002 Spring; Spec No:8–10, 4, 23–4. Comment
4244 Staskin D, Bavendam T, Miller J, et al. Effectiveness of a urinary control insert in the management of stress urinary incontinence: early results of a multicenter study. Urology. May. 1996;47(5):629-36. Not eligible target population. [pmid: 8650857].
4245 Staskin DR, Harnett MD. Effect of trospium chloride on somnolence and sleepiness in patients with overactive bladder. Curr Urol Rep. Dec. 2004;5(6):423-6. Not eligible outcomes. [pmid: 15541209].
4246 Staskin DR, Te AE. Short- and long-term efficacy of solifenacin treatment in patients with symptoms of mixed urinary incontinence. BJU Int. Jun. 2006;97(6):1256-61. Not eligible exposure. [pmid: 16686722].
4247 Steens J, Bemelman WA, Meijerink WJ, et al. Ileoanal pouch function is related to postprandial pouch tone. Br J Surg. Nov. 2001;88(11):1492-7. Case-series. [pmid: 11683747].
4248 Steers W, Corcos J, Foote J, et al. An investigation of dose titration with darifenacin, an M3-selective receptor antagonist. BJU Int. Mar. 2005;95(4):580-6. Not eligible exposure. [pmid: 15705084].
4249 Steffens J, Steffens L, Becht E, et al. Urinary undiversion after implantation of an alloplastic urethral sling for male continence. J Urol. Oct. 1994;152(4):1203-5. Case Reports. [pmid: 8072098].
4250 Steginga SK, Occhipinti S, Gardiner RA, et al. Making decisions about treatment for localized prostate cancer. BJU Int. Feb. 2002;89(3):255-60. Case-series. [pmid: 11856106].
4251 Steidle CP, Kennedy KL. Achieving a state of urinary continence for residents of nursing facilities. Part III: Manufactured incontinence. Ostomy Wound Manage. Jan–Feb. 1992;38(1):36-8. Comment.
4252 Stein A, Ratzkovitzki R, Lurie A. Perivesical fat closure during suprapubic prostatectomy: does it prevent urinary leakage? A prospective randomized study. Tech Urol. Summer. 1996;2(2):99-101. Not eligible level of evidence. [pmid: 9118417].
4253 Stein JP, Grossfeld GD, Freeman JA, et al. Orthotopic lower urinary tract reconstruction in women using the Kock ileal neobladder: updated experience in 34 patients. J Urol. Aug. 1997;158(2):400-5. Case-series. [pmid: 9224311].
4254 Stein M, Discippio W, Davia M, et al. Biofeedback for the treatment of stress and urge incontinence. J Urol. Mar. 1995;153(3 Pt 1):641-3. Not eligible target population. [pmid: 7861503].
4255 Stein M, Weinberg JJ. Polytetrafluoroethylene vs. polypropylene suture for endoscopic bladder neck suspension. Urology. Aug. 1991;38(2):119-22. Not eligible outcomes. [pmid: 1877125].
4256 Stein R, Fisch M, Beetz R, et al. Urinary diversion in children and young adults using the Mainz Pouch I technique. Br J Urol. Mar. 1997;79(3):354-61. Not eligible target population. [pmid: 9117213].
4257 Stein R, Fisch M, Black P, et al. Strategies for reconstruction after unsuccessful or unsatisfactory primary treatment of patients with bladder exstrophy or incontinent epispadias. J Urol. Jun. 1999;161(6):1934-41. Not eligible target population. [pmid: 10332476].
4258 Stein R, Hohenfellner K, Fisch M, et al. Management of bladder exstrophy and incontinent epispadias: 25 years of experience with urinary diversion. Arch Esp Urol. Jan–Feb. 1997;50(1):91-102. discussion -4. Not eligible target population. [pmid: 9086616].
4259 Stein R, Wiesner C, Beetz R, et al. Urinary diversion in children and adolescents with neurogenic bladder: the Mainz experience. Part I: Bladder augmentation and bladder substitution—therapeutic algorisms. Pediatr Nephrol. Jul. 2005;20(7):920-5. Not eligible target population. [pmid: 15856321].
4260 Steiner JF, Kramer AM, Eilertsen TB, et al. Development and validation of a clinical prediction rule for prolonged nursing home residence after hip fracture. J Am Geriatr Soc. Dec. 1997;45(12):1510-4. Not eligible outcomes. [pmid: 9400563].
4261 Steiner MS, Burnett AL, Brooks JD, et al. Tubularized neourethra following radical retropubic prostatectomy. J Urol. Aug. 1993;150(2 Pt 1):407-9. discussion 9–10. Case-series. [pmid: 8326564].
4262 Steiner MS, Morton RA, Walsh PC. Impact of anatomical radical prostatectomy on urinary continence. J Urol. Mar. 1991;145(3):512-4. discussion 4–5. Question 2. [pmid: 1997701].
4263 Stelling JD, Hale AM. Protocol for changing condom catheters in males with spinal cord injury. SCI Nurs. Jun. 1996;13(2):28-34. Not eligible outcomes. [pmid: 8900706].
4264 Stephenson AJ, Scardino PT, Bianco FJ Jr, et al. Morbidity and functional outcomes of salvage radical prostatectomy for locally recurrent prostate cancer after radiation therapy. J Urol. Dec. 2004;172(6 Pt 1):2239-43. Case-series. [pmid: 15538239].
4265 Sterbis JR, Lewis VL, Bushman W. Urologic and plastic surgical collaboration for continent diversion when urine leakage is complicated by pressure ulcers or obesity. J Spinal Cord Med. Summer. 2003;26(2):124-8. Case-series. [pmid: 12828288].
4266 Stern JA, Clemens JQ, Tiplitsky SI, et al. Long-term results of the bulbourethral sling procedure. J Urol. May. 2005;173(5):1654-6. Case-series. [pmid: 15821529].
4267 Stern RM, Vitellaro K, Thomas M, et al. Electrogastrographic biofeedback: a technique for enhancing normal gastric activity. Neurogastroenterol Motil. Dec. 2004;16(6):753-7. Not eligible outcomes. [pmid: 15601425].
4268 Steven K, Poulsen AL. The orthotopic Kock ileal neobladder: functional results, urodynamic features, complications and survival in 166 men. J Urol. Aug. 2000;164(2):288-95. Not eligible level of evidence. [pmid: 10893568].
4269 Stewart DA, Taylor J, Ghosh S, et al. Terodiline causes polymorphic ventricular tachycardia due to reduced heart rate and prolongation of QT interval. Eur J Clin Pharmacol. 1992;42(6):577-80. Case Reports. [pmid: 1623896].
4270 Stewart J, Kumar D, Keighley MR. Results of anal or low rectal anastomosis and pouch construction for megarectum and megacolon. Br J Surg. Jul. 1994;81(7):1051-3. Not eligible target population. [pmid: 7922062].
4271 Stewart ST, Lenert L, Bhatnagar V, et al. Utilities for prostate cancer health states in men aged 60 and older. Med Care. Apr. 2005;43(4):347-55. Not eligible outcomes. [pmid: 15778638].
4272 Stickler DJ, King JB, Winters C, et al. Blockage of urethral catheters by bacterial biofilms. J Infect. Sep. 1993;27(2):133-5. Case- Reports. [pmid: 8228293].
4273 Stikkelbroeck NM, Beerendonk CC, Willemsen WN, et al. The long term outcome of feminizing genital surgery for congenital adrenal hyperplasia: anatomical, functional and cosmetic outcomes, psychosexual development, and satisfaction in adult female patients. J Pediatr Adolesc Gynecol. Oct. 2003;16(5):289-96. Not eligible exposure. [pmid: 14597017].
4274 Stocchi F, Badiali D, Vacca L, et al. Anorectal function in multiple system atrophy and Parkinson's disease. Mov Disord. Jan. 2000;15(1):71-6. Not eligible exposure. [pmid: 10634244].
4275 Stock RG, Stone NN, DeWyngaert JK, et al. Prostate specific antigen findings and biopsy results following interactive ultrasound guided transperineal brachytherapy for early stage prostate carcinoma. Cancer. Jun 1. 1996;77(11):2386-92. Not eligible target population. [pmid: 8635111].
4276 Stoffel JT, McGuire EJ. Outcome of urethral closure in patients with neurologic impairment and complete urethral destruction. Neurourol Urodyn. 2006;25(1):19-22. Case-series. [pmid: 16173042].
4277 Stoffel JT, Oh SJ, McGuire EJ. Technique for removal of symptomatic bone anchors placed during stress incontinence surgery. Urology. Mar. 2005;65(3):583-6. Case-series. [pmid: 15780382].
4278 Stojkovic SG, Balfour L, Burke D, et al. Role of resting pressure gradient in the investigation of idiopathic fecal incontinence. Dis Colon Rectum. May. 2002;45(5):668-73. Not eligible outcomes. [pmid: 12004218].
4279 Stoker J, Rociu E, Bosch JL, et al. High-resolution endovaginal MR imaging in stress urinary incontinence. Eur Radiol. Aug. 2003;13(8):2031-7. Not eligible outcomes. [pmid: 12692675].
4280 Stolzenburg JU, Liatsikos EN, Rabenalt R, et al. Nerve sparing endoscopic extraperitoneal radical prostatectomy—effect of puboprostatic ligament preservation on early continence and positive margins. Eur Urol. Jan. 2006;49(1):103-11. discussion 11–2. Case series. [pmid: 16314031].
4281 Stolzenburg JU, Rabenalt R, Do M, et al. Nerve-sparing endoscopic extraperitoneal radical prostatectomy: University of Leipzig technique. J Endourol. Nov. 2006;20(11):925-9. Case series. [pmid: 17144866].
4282 Stone JM, Wolfe VA, Nino-Murcia M, et al. Colostomy as treatment for complications of spinal cord injury. Arch Phys Med Rehabil. Jun. 1990;71(7):514-8. Case-series. [pmid: 2350223].
4283 Storch JS. Lumbar burst fracture associated with bowel, bladder, and sexual dysfunction: case study. J Neurosci Nurs. Apr. 2005;37(2):68-71. Case report. [pmid: 15902947].
4284 Strasser H, Klima G, Poisel S, et al. Anatomy and innervation of the rhabdosphincter of the male urethra. Prostate. Jan. 1996;28(1):24-31. Not eligible target population. [pmid: 8545278].
4285 Strasser H, Tiefenthaler M, Steinlechner M, et al. Age dependent apoptosis and loss of rhabdosphincter cells. J Urol. Nov. 2000;164(5):1781-5. Not eligible outcomes. [pmid: 11025769].
4286 Strohbehn K, Quint LE, Prince MR, et al. Magnetic resonance imaging anatomy of the female urethra: a direct histologic comparison. Obstet Gynecol. Nov. 1996;88(5):750-6. Case-series. [pmid: 8885907].
4287 Stromberg J, Martinez A, Benson R, et al. Improved local control and survival for surgically staged patients with locally advanced prostate cancer treated with up-front low dose rate iridium-192 prostate implantation and external beam irradiation. Int J Radiat Oncol Biol Phys. Jan 1. 1994;28(1):67-75. No associative hypothesis tested. [pmid: 8270460].
4288 Su TH, Huang JP, Wang YL, et al. Is modified in situ vaginal wall sling operation the treatment of choice for recurrent genuine stress incontinence?. J Urol. Dec. 1999;162(6):2073-7. Not eligible target population. [pmid: 10569573].
4289 Su TH, Wang KG, Hsu CY, et al. Periurethral fat injection in the treatment of recurrent genuine stress incontinence. J Urol. Feb. 1998;159(2):411-4. Not eligible target population. [pmid: 9649251].
4290 Subak LL, Brown JS, Kraus SR, et al. The “costs” of urinary incontinence for women. Obstet Gynecol. Apr. 2006;107(4):908-16. Not eligible outcomes. [pmid: 16582131]. [pmcid: 1557394].
4291 Subak LL, Johnson C, Whitcomb E, et al. Does weight loss improve incontinence in moderately obese women?. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(1):40-3. Case-series. [pmid: 11999205].
4292 Sueppel C, Arthur C, Van Why K, et al. A comprehensive screening program for urinary dysfunction in older adults. Urol Nurs. Mar. 1996;16(1):14-9. Not eligible outcomes. [pmid: 8826390].
4293 Sueppel C, Kreder K, See W. Improved continence outcomes with preoperative pelvic floor muscle strengthening exercises. Urol Nurs. Jun. 2001;21(3):201-10. Review. [pmid: 11998651].
4294 Sugarman ID, Malone PS, Terry TR, et al. Transversely tubularized ileal segments for the Mitrofanoff or Malone antegrade colonic enema procedures: the Monti principle. Br J Urol. Feb. 1998;81(2):253-6. Not eligible target population. [pmid: 9488068].
4295 Sugaya K, Nishijima S, Oda M, et al. Transabdominal vesical sonography of urethral syndrome and stress incontinence. Int J Urol. Jan. 2003;10(1):36-42. Not eligible outcomes. [pmid: 12534925].
4296 Sugaya K, Nishizawa O, Satoh T, et al. Bladder-pumping therapy for the treatment of low-capacity or low-compliance bladders. Neurourol Urodyn. 2000;19(1):19-28. Case-series. [pmid: 10602245].
4297 Sugaya K, Owan T, Hatano T, et al. Device to promote pelvic floor muscle training for stress incontinence. Int J Urol. Aug. 2003;10(8):416-22. Not eligible target population. [pmid: 12887362].
4298 Sugerman HJ, Felton WL 3rd, Salvant JB Jr, et al. Effects of surgically induced weight loss on idiopathic intracranial hypertension in morbid obesity. Neurology. Sep. 1995;45(9):1655-9. Case-series. [pmid: 7675222].
4299 Sugerman HJ, Felton WL 3rd, Sismanis A, et al. Gastric surgery for pseudotumor cerebri associated with severe obesity. Ann Surg. May. 1999;229(5):634-40. discussion 40–2. Not eligible exposure. [pmid: 10235521]. [pmcid: 1420807].
4300 Sugerman HJ, Sugerman EL, Wolfe L, et al. Risks and benefits of gastric bypass in morbidly obese patients with severe venous stasis disease. Ann Surg. Jul. 2001;234(1):41-6. Not eligible level of evidence. [pmid: 11460821]. [pmcid: 1421946].
4301 Sugerman HJ, Wolfe LG, Sica DA, et al. Diabetes and hypertension in severe obesity and effects of gastric bypass-induced weight loss. Ann Surg. Jun. 2003;237(6):751-6. discussion 7–8. Not eligible level of evidence. [pmid: 12796570]. [pmcid: 1514677].
4302 Sugimura Y, Hioki T, Yamada Y, et al. An anterior urethral stitch improves urinary incontinence following radical prostatectomy. Int J Urol. Apr. 2001;8(4):153-7. Case-series. [pmid: 11260346].
4303 Sugiyama T, Hashimoto K, Kiwamoto H, et al. Urinary incontinence in senile dementia of the Alzheimer type (SDAT). Int J Urol. Dec. 1994;1(4):337-40. Case-series. [pmid: 7614397].
4304 Suilleabhain CB, Horgan AF, McEnroe L, et al. The relationship of pudendal nerve terminal motor latency to squeeze pressure in patients with idiopathic fecal incontinence. Dis Colon Rectum. May. 2001;44(5):666-71. Not eligible outcomes. [pmid: 11357026].
4305 Suita S, Taguchi T, Yanai K, et al. Longterm outcomes and quality of life after Z-shaped anastomosis for Hirschsprung's disease. J Am Coll Surg. Dec. 1998;187(6):577-83. Not eligible target population. [pmid: 9849729].
4306 Sulak PJ, Kuehl TJ, Shull BL. Vaginal pessaries and their use in pelvic relaxation. J Reprod Med. Dec. 1993;38(12):919-23. Case-series. [pmid: 8120847].
4307 Sultan AH, Kamm MA, Hudson CN, et al. Anal-sphincter disruption during vaginal delivery. N Engl J Med. Dec 23. 1993;329(26):1905-11. Not eligible level of evidence. [pmid: 8247054].
4308 Sultan AH, Kamm MA, Nicholls RJ, et al. Prospective study of the extent of internal anal sphincter division during lateral sphincterotomy. Dis Colon Rectum. Oct. 1994;37(10):1031-3. Case-series. [pmid: 7924711].
4309 Sultan AH, Kamm MA, Talbot IC, et al. Anal endosonography for identifying external sphincter defects confirmed histologically. Br J Surg. Mar. 1994;81(3):463-5. Not eligible outcomes. [pmid: 8173933].
4310 Sultan AH, Loder PB, Bartram CI, et al. Vaginal endosonography. New approach to image the undisturbed anal sphincter. Dis Colon Rectum. Dec. 1994;37(12):1296-9. Not eligible outcomes. [pmid: 7995162].
4311 Sultan AH, Monga AK, Kumar D, et al. Primary repair of obstetric anal sphincter rupture using the overlap technique. Br J Obstet Gynaecol. Apr. 1999;106(4):318-23. Not eligible outcomes. [pmid: 10426237].
4312 Sumathi VP, Murnaghan M, Dobbs SP, et al. Extragenital mullerian carcinosarcoma arising from the peritoneum: report of two cases. Int J Gynecol Cancer. Nov–Dec. 2002;12(6):764-7. Not eligible exposure. [pmid: 12445257].
4313 Sumi T, Ishiko O, Hirai K, et al. Is measuring the posterior urethrovesical angle of clinical value for controlling pelvic organ Prolapse?. Retrospective analysis of 107 postoperative cases. Gynecol Obstet Invest. 2000;49(3):183-6. Case-series. [pmid: 10729759].
4314 Sumiya T, Kawamura K, Tokuhiro A, et al. A survey of wheelchair use by paraplegic individuals in Japan. Part 2: Prevalence of pressure sores. Spinal Cord. Sep. 1997;35(9):595-8. Not eligible outcomes. [pmid: 9300965].
4315 Sun MJ, Chang SY, Lin KC, et al. Is an indwelling catheter necessary for bladder drainage after modified Burch colposuspension?. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):203-7. Not eligible exposure. [pmid: 15168002].
4316 Sun MJ, Chen GD, Chang SY, et al. Prevalence of lower urinary tract symptoms during pregnancy in Taiwan. J Formos Med Assoc. Mar. 2005;104(3):185-9. Not eligible level of evidence. [pmid: 15818433].
4317 Sun MJ, Chen GD, Lin KC. Obturator hematoma after the transobturator suburethral tape procedure. Obstet Gynecol. Sep. 2006;108(3 Pt 2):716-8. Case Reports. [pmid: 17018475].
4318 Sun MJ, Ng SC, Tsui KP, et al. Are there any predictors for failed Burch colposuspension?. Taiwan J Obstet Gynecol. Mar. 2006;45(1):33-8. Case-series. [pmid: 17272205].
4319 Sun WM, Donnelly TC, Read NW. Utility of a combined test of anorectal manometry, electromyography, and sensation in determining the mechanism of ‘idiopathic’ faecal incontinence. Gut. Jun. 1992;33(6):807-13. Not eligible outcomes. [pmid: 1624164]. [pmcid: 1379341].
4320 Sun WM, Katsinelos P, Horowitz M, et al. Disturbances in anorectal function in patients with diabetes mellitus and faecal incontinence. Eur J Gastroenterol Hepatol. Oct. 1996;8(10):1007-12. Case-series. [pmid: 8930568].
4321 Sun WM, Read NW, Donnelly TC. Anorectal function in incontinent patients with cerebrospinal disease. Gastroenterology. Nov. 1990;99(5):1372-9. Not eligible outcomes. [pmid: 2210244].
4322 Sun WM, Read NW, Katsinelos P, et al. Anorectal function after restorative proctocolectomy and low anterior resection with coloanal anastomosis. Br J Surg. Feb. 1994;81(2):280-4. Case-series. [pmid: 8156360].
4323 Sun WM, Read NW, Miner PB. Relation between rectal sensation and anal function in normal subjects and patients with faecal incontinence. Gut. Sep. 1990;31(9):1056-61. Not eligible outcomes. [pmid: 2210452]. [pmcid: 1378669].
4324 Sun WM, Read NW, Miner PB, et al. The role of transient internal sphincter relaxation in faecal incontinence?. Int J Colorectal Dis. Feb. 1990;5(1):31-6. Not eligible outcomes. [pmid: 2313154].
4325 Sungurtekin U, Sungurtekin H, Kabay B, et al. Anocutaneous V-Y advancement flap for the treatment of complex perianal fistula. Dis Colon Rectum. Dec. 2004;47(12):2178-83. Not eligible exposure. [pmid: 15657671].
4326 Surer I, Baker LA, Jeffs RD, et al. Modified Young-Dees-Leadbetter bladder neck reconstruction in patients with successful primary bladder closure elsewhere: a single institution experience. J Urol. Jun. 2001;165(6 Pt 2):2438-40. Case-series. [pmid: 11371993].
4327 Susset J, Galea G, Manbeck K, et al. A predictive score index for the outcome of associated biofeedback and vaginal electrical stimulation in the treatment of female incontinence. J Urol. May. 1995;153(5):1461-6. Case-series. [pmid: 7714966].
4328 Susset JG, Galea G, Read L. Biofeedback therapy for female incontinence due to low urethral resistance. J Urol. Jun. 1990;143(6):1205-8. Case-series. [pmid: 2342183].
4329 Sustersic O, Kralj B. The influence of obesity, constitution and physical work on the phenomenon of urinary incontinence in women. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(3):140-4. Question 2. [pmid: 9745972].
4330 Suzuki K, Meguro K, Wada M, et al. Anterior spinal artery syndrome associated with severe stenosis of the vertebral artery. AJNR Am J Neuroradiol. Aug. 1998;19(7):1353-5. Case report. [pmid: 9726482].
4331 Sveen U, Thommessen B, Bautz-Holter E, et al. Well-being and instrumental activities of daily living after stroke. Clin Rehabil. May. 2004;18(3):267-74. Case-series. [pmid: 15137558].
4332 Swaddiwudhipong W, Koonchote S, Nguntra P, et al. Assessment of socio-economic, functional and medical problems among the elderly in one rural community of Thailand. Southeast Asian J Trop Med Public Health. Sep. 1991;22(3):299-306. Not eligible level of evidence. [pmid: 1818379].
4333 Swain RA. Exercise-induced diarrhea: when to wonder. Med Sci Sports Exerc. May. 1994;26(5):523-6. Not eligible exposure. [pmid: 8007797].
4334 Swami KS, Jurriaans E, Hammonds JC. The wider spectrum of megalourethra. Br J Urol. Apr. 1995;75(4):563. Not eligible exposure. [pmid: 7788279].
4335 Swanson JG, Skelly J, Hutchison B, et al. Urinary incontinence in Canada. National survey of family physicians' knowledge, attitudes, and practices. Can Fam Physician. Jan. 2002;48:86-92. Not eligible outcomes. [pmid: 11852616]. [pmcid: 2213918].
4336 Sweat SD, Itano NB, Clemens JQ, et al. Polypropylene mesh tape for stress urinary incontinence: complications of urethral erosion and outlet obstruction. J Urol. Jul. 2002;168(1):144-6. Not eligible exposure. [pmid: 12050509].
4337 Sweat SD, Lightner DJ. Complications of sterile abscess formation and pulmonary embolism following periurethral bulking agents. J Urol. Jan. 1999;161(1):93-6. Not eligible outcomes. [pmid: 10037377].
4338 Swierzewski SJ 3rd, Gormley EA, Belville WD, et al. The effect of terazosin on bladder function in the spinal cord injured patient. J Urol. Apr. 1994;151(4):951-4. Case-series. [pmid: 7907374].
4339 Swierzewski SJ 3rd, McGuire EJ. Pubovaginal sling for treatment of female stress urinary incontinence complicated by urethral diverticulum. J Urol. May. 1993;149(5):1012-4. Case-series. [pmid: 8483202].
4340 Swierzewski SJ 3rd, McGuire EJ, Podrazik RM, et al. Aortic occlusion and lower extremity exercise induced stress urinary incontinence. J Urol. Apr. 1993;149(4):846-7. Case Reports. [pmid: 8455256].
4341 Swift S, Garely A, Dimpfl T, et al. A new once-daily formulation of tolterodine provides superior efficacy and is well tolerated in women with overactive bladder. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):50-4. discussion 4–5. Not eligible exposure. [pmid: 12601517].
4342 Swift S, Woodman P, O'Boyle A, et al. Pelvic Organ Support Study (POSST): the distribution, clinical definition, and epidemiologic condition of pelvic organ support defects. Am J Obstet Gynecol. Mar. 2005;192(3):795-806. Not eligible outcomes. [pmid: 15746674].
4343 Swift SE, Rust PF, Ostergard DR. Intrasubject variability of the pressure-transmission ratio in patients with genuine stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(6):312-6. [pmid: 9203478].
4344 Swift SE, Yoon EA. Test-retest reliability of the cough stress test in the evaluation of urinary incontinence. Obstet Gynecol. Jul. 1999;94(1):99-102. Not eligible outcomes. [pmid: 10389726].
4345 Swithinbank L, Abrams P. Lower urinary tract symptoms in community-dwelling women: defining diurnal and nocturnal frequency and ‘the incontinence case’. BJU Int. Sep. 2001;88(Suppl 2):18-22. discussion 49–50. Not eligible outcomes.
4346 Swithinbank LV, Donovan JL, Rogers CA, et al. Nocturnal incontinence in women: a hidden problem. J Urol. Sep. 2000;164(3 Pt 1):764-6. Not eligible outcomes. [pmid: 10953142].
4347 Sykes D, Castro R, Pons ME, et al. Characteristics of female outpatients with urinary incontinence participating in a 6-month observational study in 14 European countries. Maturitas. Nov 30. 2005;52(Suppl 2):S13-23. Not eligible level of evidence. [pmid: 16297580].
4348 Szabo L, Lombay B, Borbas E, et al. Videourodynamics in the diagnosis of urinary tract abnormalities in a single center. Pediatr Nephrol. Mar. 2004;19(3):326-31. Not eligible target population. [pmid: 14689290].
4349 Sze EH, Kohli N, Miklos JR, et al. A retrospective comparison of abdominal sacrocolpopexy with Burch colposuspension versus sacrospinous fixation with transvaginal needle suspension for the management of vaginal vault prolapse and coexisting stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(6):390-3. Case-series. [pmid: 10614976].
4350 Sze EH, Kohli N, Miklos JR, et al. Comparative morbidity and charges associated with route of hysterectomy and concomitant Burch colposuspension. Obstet Gynecol. Jul. 1997;90(1):42-5. Case-series. [pmid: 9207810].
4351 Sze EH, Miklos JR, Partoll L, et al. Sacrospinous ligament fixation with transvaginal needle suspension for advanced pelvic organ prolapse and stress incontinence. Obstet Gynecol. Jan. 1997;89(1):94-6. Not eligible target population. [pmid: 8990446].
4352 Sze KH, Wong E, Leung HY, et al. Falls among Chinese stroke patients during rehabilitation. Arch Phys Med Rehabil. Sep. 2001;82(9):1219-25. Not eligible outcomes. [pmid: 11552194].
4353 Sze KH, Wong E, Or KH, et al. Factors predicting stroke disability at discharge: a study of 793 Chinese. Arch Phys Med Rehabil. Jul. 2000;81(7):876-80. Not eligible outcomes. [pmid: 10895998].
4354 Szonyi G, Collas DM, Ding YY, et al. Oxybutynin with bladder retraining for detrusor instability in elderly people: a randomized controlled trial. Age Ageing. Jul. 1995;24(4):287-91. Not eligible exposure. [pmid: 7484484].
4355 Tabbara IA, Sibley DS, Quesenberry PJ. Spinal cord compression due to metastatic neoplasm. South Med J. May. 1990;83(5):519-23. Case-series. [pmid: 2343331].
4356 Tabibian L, Ginsberg DA. Transurethral collagen injection in neuropathic sphincter deficiency. Topics in Spinal Cord Injury Rehabilitation. Winter. 2003;8(3):54-9. Case-series.
4357 Tainio H, Kylmala T, Tammela TL. Ulcer perforation in gastric urinary conduit: never use a gastric segment in the urinary tract if there are other options available. Urol Int. 2000;64(2):101-2. discussion 3. Case Reports. [pmid: 10810273].
4358 Takahashi S, Homma Y, Fujishiro T, et al. Electromyographic study of the striated urethral sphincter in type 3 stress incontinence: evidence of myogenic-dominant damages. Urology. Dec 20. 2000;56(6):946-50. Not eligible outcomes. [pmid: 11113738].
4359 Takahashi S, Miyao N, Hisataki T, et al. Complications of Stamey needle suspension for female stress urinary incontinence. Urol Int. 2002;68(3):148-51. Case-series. [pmid: 11919458].
4360 Takahashi S, Tajima A, Matsushima H, et al. Clinical efficacy of an alpha1A/D-adrenoceptor blocker (naftopidil) on overactive bladder symptoms in patients with benign prostatic hyperplasia. Int J Urol. Jan. 2006;13(1):15-20. Case-series. [pmid: 16448426].
4361 Takahashi T, Garcia-Osogobio S, Valdovinos MA, et al. Extended two-year results of radio-frequency energy delivery for the treatment of fecal incontinence (the Secca procedure). Dis Colon Rectum. Jun. 2003;46(6):711-5. Case-series. [pmid: 12794570].
4362 Takahashi T, Garcia-Osogobio S, Valdovinos MA, et al. Radio-frequency energy delivery to the anal canal for the treatment of fecal incontinence. Dis Colon Rectum. Jul. 2002;45(7):915-22. Case-series. [pmid: 12130880].
4363 Takano K, Yamaguchi T, Minematsu K, et al. Differences in clinical features and computed tomographic findings between embolic and non-embolic acute ischemic stroke: a quantitative differential diagnosis. Intern Med. Feb. 1998;37(2):141-8. Not eligible outcomes. [pmid: 9550593].
4364 Takano M, Hamada A. Evaluation of pelvic descent disorders by dynamic contrast roentgenography. Dis Colon Rectum. Oct. 2000;43(10 Suppl):S6-11. Not eligible exposure. [pmid: 11052471].
4365 Takao Y, Gilliland R, Nogueras JJ, et al. Is age relevant to functional outcome after restorative proctocolectomy for ulcerative colitis?: prospective assessment of 122 cases. Ann Surg. Feb. 1998;227(2):187-94. Case-series. [pmid: 9488515]. [pmcid: 1191234].
4366 Takazawa K, Arisawa K. Relationship between the type of urinary incontinence and falls among frail elderly women in Japan. J Med Invest. Aug. 2005;52(34):165-71. Case-series. [pmid: 16167534].
4367 Takeda M, Hatano A, Kurumada S, et al. Bladder neck suspension using percutaneous bladder neck stabilization to the pubic bone with a bone-anchor suture fixation system: A new extraperitoneal laparoscopic approach. Urol Int. 1999;62(1):57-60. Case Reports. [pmid: 10436436].
4368 Takei M, Homma Y. Long-term safety, tolerability and efficacy of extended-release tolterodine in the treatment of overactive bladder in Japanese patients. Int J Urol. May. 2005;12(5):456-64. Not eligible exposure. [pmid: 15948744].
4369 Takenaka A, Hara R, Soga H, et al. A novel technique for approaching the endopelvic fascia in retropubic radical prostatectomy, based on an anatomical study of fixed and fresh cadavers. BJU Int. Apr. 2005;95(6):766-71. Case-series. [pmid: 15794779].
4370 Takesue Y, Yokoyama T, Kodama T, et al. Influence of ileal pouch capacity and anal sphincteric function on the clinical outcome after ileal pouch-anal anastomosis. Surg Today. 1997;27(5):392-7. Case-series. [pmid: 9130339].
4371 Tal S, Gurevich A, Guller V, et al. Risk factors for recurrence of Clostridium difficile-associated diarrhea in the elderly. Scand J Infect Dis. 2002;34(8):594-7. Not eligible outcomes. [pmid: 12238576].
4372 Talbot LA, Cox M. Differences in coping strategies among community-residing older adults with functional urinary continence, dysfunctional urinary continence and actual urinary incontinence. Ostomy Wound Manage 1995 Nov–Dec; 41(10):30–2, 4–7. Not eligible outcomes
4373 Talcott JA, Clark JA, Manola J, et al. Bringing prostate cancer quality of life research back to the bedside: translating numbers into a format that patients can understand. J Urol. Oct. 2006;176(4 Pt 1):1558-63. discussion 63–4. Not eligible outcomes. [pmid: 16952681].
4374 Talcott JA, Clark JA, Stark PC, et al. Long-term treatment related complications of brachytherapy for early prostate cancer: a survey of patients previously treated. J Urol. Aug. 2001;166(2):494-9. Case-series. [pmid: 11458054].
4375 Talcott JA, Rieker P, Propert KJ, et al. Patient-reported impotence and incontinence after nerve-sparing radical prostatectomy. J Natl Cancer Inst. Aug 6. 1997;89(15):1117-23. No associative hypothesis tested. [pmid: 9262249].
4376 Talley NJ, Young L, Bytzer P, et al. Impact of chronic gastrointestinal symptoms in diabetes mellitus on health-related quality of life. Am J Gastroenterol. Jan. 2001;96(1):71-6. Not eligible level of evidence. [pmid: 11197290].
4377 Tamanini JT, Dambros M, D'Ancona CA, et al. Responsiveness to the Portuguese version of the International Consultation on Incontinence Questionnaire-Short Form (ICIQ-SF) after stress urinary incontinence surgery. Int Braz J Urol. Sep–Oct. 2005;31(5):482-9. discussion 90. Not eligible exposure. [pmid: 16255798].
4378 Tamanini JT, D'Ancona CA, Netto NR. Macroplastique implantation system for female stress urinary incontinence: long-term follow-up. J Endourol. Dec. 2006;20(12):1082-6. Case-series. [pmid: 17206907].
4379 Tamanini JT, D'Ancona CA, Tadini V, et al. Macroplastique implantation system for the treatment of female stress urinary incontinence. J Urol. Jun. 2003;169(6):2229-33. Not eligible target population. [pmid: 12771756].
4380 Tamilselvi A, Duckett JR. Surgical correction of genuine stress incontinence in an achondroplastic woman. J Obstet Gynaecol. Nov. 2002;22(6):704. Case Reports.
4381 Tampakoudis P, Tantanassis T, Grimbizis G, et al. Cigarette smoking and urinary incontinence in women—a new calculative method of estimating the exposure to smoke. Eur J Obstet Gynecol Reprod Biol. Nov. 1995;63(1):27-30. Not eligible level of evidence. [pmid: 8674561].
4382 Tamura T, Nakajima K, Matsushita T, et al. A warning detector for urinary incontinence for home health care. Biomed Instrum Technol. Jul–Aug. 1995;29(4):343-9. Not eligible exposure. [pmid: 7550501].
4383 Tamussino KF, Hanzal E, Kolle D, et al. Tension-free vaginal tape operation: results of the Austrian registry. Obstet Gynecol. Nov. 2001;98(5 Pt 1):732-6. Not eligible outcomes. [pmid: 11704161].
4384 Tan AH, Gilling PJ, Kennett KM, et al. Long-term results of high-power holmium laser vaporization (ablation) of the prostate. BJU Int. Nov. 2003;92(7):707-9. Case-series. [pmid: 14616451].
4385 Tan M, O'Hanlon DM, Cassidy M, et al. Advantages of a posterior fourchette incision in anal sphincter repair. Dis Colon Rectum. Nov. 2001;44(11):1624-9. Case-series. [pmid: 11711734].
4386 Tan TL, Bergmann MA, Griffiths D, et al. Which stop test is best? Measuring detrusor contractility in older females. J Urol. Mar. 2003;169(3):1023-7. Not eligible outcomes. [pmid: 12576837].
4387 Tanaka S, Kubota M, Fujimoto Y, et al. Conus medullaris syndrome secondary to an L1 burst fracture in osteoporosis. A case report. Spine. Oct 15. 1993;18(14):2131-4. Case Reports. [pmid: 8272970].
4388 Tanaka T, Kitamura H, Takahashi A, et al. Long-term functional outcome and late complications of Studer's ileal neobladder. Jpn J Clin Oncol. Jul. 2005;35(7):391-4. Case-series. [pmid: 15976064].
4389 Tancer ML, Lasser D, Rosenblum N. Rectovaginal fistula or perineal and anal sphincter disruption, or both, after vaginal delivery. Surg Gynecol Obstet. Jul. 1990;171(1):43-6. Case-series. [pmid: 2193413].
4390 Tang WK, Chan SS, Chiu HF, et al. Frequency and determinants of poststroke dementia in Chinese. Stroke. Apr. 2004;35(4):930-5. Not eligible level of evidence. [pmid: 14976325].
4391 Tang WK, Chan SS, Chiu HF, et al. Frequency and clinical determinants of poststroke cognitive impairment in nondemented stroke patients. J Geriatr Psychiatry Neurol. Jun. 2006;19(2):65-71. Not eligible outcomes. [pmid: 16690990].
4392 Tankova L, Draganov V, Damyanov N. Endosonography for assessment of anorectal changes in patients with fecal incontinence. Eur J Ultrasound. Mar. 2001;12(3):221-5. Not eligible outcomes. [pmid: 11423246].
4393 Tannenbaum C, Bachand G, Dubeau CE, et al. Experience of an incontinence clinic for older women: no apparent age limit for potential physical and psychological benefits. J Womens Health Gend Based Med. Oct. 2001;10(8):751-6. Case-series. [pmid: 11703887].
4394 Tannenbaum C, Labrecque D, Lepage C. Understanding barriers to continence care in institutions. Can J Aging. Summer. 2005;24(2):151-9. Not eligible target population. [pmid: 16082618].
4395 Tapp AJ, Cardozo LD, Versi E, et al. The treatment of detrusor instability in post-menopausal women with oxybutynin chloride: a double blind placebo controlled study. Br J Obstet Gynaecol. Jun. 1990;97(6):521-6. Not eligible exposure. [pmid: 2198921].
4396 Tapp K, Connolly A, Visco AG. Evaluation of Aa point and cotton-tipped swab test as predictors of urodynamic stress incontinence. Obstet Gynecol. Jan. 2005;105(1):115-9. Not eligible outcomes. [pmid: 15625151].
4397 Tarbox RS, Williams WL, Friman PC. Extended diaper wearing: effects on continence in and out of the diaper. J Appl Behav Anal. Spring. 2004;37(1):97-100. Case Reports. [pmid: 15154222]. [pmcid: 1284484].
4398 Tarvonen-Schroder S, Roytta M, Raiha I, et al. Clinical features of leuko-araiosis. J Neurol Neurosurg Psychiatry. Apr. 1996;60(4):431-6. Not eligible exposure. [pmid: 8774411]. [pmcid: 1073899].
4399 Taskinen S, Valanne L, Rintala R. Effect of spinal cord abnormalities on the function of the lower urinary tract in patients with anorectal abnormalities. J Urol. Sep. 2002;168(3):1147-9. Not eligible outcomes. [pmid: 12187257].
4400 Tate SB, Franco AV, Fynes MM. Tension-free vaginal tape exposure presenting as a recurrent sterile paraurethral abscess. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):420-3. Case Reports. [pmid: 15846455].
4401 Taub DA, Hollenbeck BK, Wei JT, et al. Complications following surgical intervention for stress urinary incontinence: a national perspective. Neurourol Urodyn. 2005;24(7):659-65. Not eligible outcomes. [pmid: 16173038].
4402 Taub NA, Wolfe CD, Richardson E, et al. Predicting the disability of first-time stroke sufferers at 1 year. 12-month follow-up of a population-based cohort in southeast England. Stroke. Feb. 1994;25(2):352-7. Not eligible outcomes. [pmid: 8303744].
4403 Taunton RL, Swagerty DL, Lasseter JA, et al. Continent or incontinent? That is the question. J Gerontol Nurs. Sep. 2005;31(9):36-44. Case-series. [pmid: 16190011].
4404 Tay KP, Lim PH, Chng HC. Surgical management of stress urinary incontinence: Burch colposuspension, modified Pereyra and Stamey bladder neck suspension, and collagen injection—Toa Payoh Hospital experience. Singapore Med J. Dec. 1995;36(6):651-5. Case-series. [pmid: 8781641].
4405 Tay KP, Lim PH, Ravintharan T. Laparoscopic bladder-neck suspension for urinary stress incontinence in women: our first twenty patients. Int J Urol. Jul. 1996;3(4):278-81. Case-series. [pmid: 8844283].
4406 Taylor PH, Sussman DO. Contemporary treatment options for overactive bladder. Jaapa 2005 Nov; Suppl:3–13; quiz 4–5. No associative hypothesis tested
4407 Taylor RF, Beard MV. Normal pressure hydrocephalus and deep white matter stroke: a case report. Arch Phys Med Rehabil. Sep. 1997;78(9):1015-8. Case report. [pmid: 9305280].
4408 Tchetgen MB, Sanda MG, Montie JE, et al. Collagen injection for the treatment of incontinence after cystectomy and orthotopic neobladder reconstruction in women. J Urol. Jan. 2000;163(1):212-4. Case-series. [pmid: 10604350].
4409 Te AE, Malloy TR, Stein BS, et al. Impact of prostate-specific antigen level and prostate volume as predictors of efficacy in photoselective vaporization prostatectomy: analysis and results of an ongoing prospective multicentre study at 3 years. BJU Int. Jun. 2006;97(6):1229-33. Not eligible exposure. [pmid: 16686717].
4410 Tediosi F, Parazzini F, Bortolotti A, et al. The cost of urinary incontinence in Italian women. A cross-sectional study. Gruppo di Studio Incontinenza. Pharmacoeconomics. Jan. 2000;17(1):71-6. Not eligible level of evidence. [pmid: 10747766].
4411 Tefilli MV, Gheiler EL, Tiguert R, et al. Quality of life in patients undergoing salvage procedures for locally recurrent prostate cancer. J Surg Oncol. Nov. 1998;69(3):156-61. Not eligible outcomes. [pmid: 9846502].
4412 Tei TM, Stolzenburg T, Buntzen S, et al. Use of transpelvic rectus abdominis musculocutaneous flap for anal cancer salvage surgery. Br J Surg. May. 2003;90(5):575-80. Not eligible level of evidence. [pmid: 12734865].
4413 Teichman JM, Barber DB, Rogenes VJ, et al. Malone antegrade continence enemas for autonomic dysreflexia secondary to neurogenic bowel. J Spinal Cord Med. Jul. 1998;21(3):245-7. Case Reports. [pmid: 9863936].
4414 Teichman JM, Harris JM, Currie DM, et al. Malone antegrade continence enema for adults with neurogenic bowel disease. J Urol. Oct. 1998;160(4):1278-81. Case-series. [pmid: 9751335].
4415 Teichman JM, Rogenes VJ, Barber DB. The malone antegrade continence enema combined with urinary diversion in adult neurogenic patients: early results. Urology. Jun. 1997;49(6):963-7. Case Reports. [pmid: 9187713].
4416 Teichman JM, Rogenes VJ, Barber DB. The utility of the Malone antegrade continence enema for urologists. Tech Urol. Spring. 1997;3(1):30-3. Case- Reports. [pmid: 9170222].
4417 Tejada Cabrera M, Lopez Cano A, Munoz Benvenuty A. Anal incontinence: evaluation of the anal sphincter by endoscopic ultrasound. Rev Esp Enferm Dig. May. 2005;97(5):375-6. Case-reports. [pmid: 16004528].
4418 Telander RL, Spencer M, Perrault J, et al. Long-term follow-up of the ileoanal anastomosis in children and young adults. Surgery. Oct. 1990;108(4):717-23. discussion 23–5. Not eligible target population. [pmid: 2218884].
4419 Telford KJ, Ali AS, Lymer K, et al. Fatigability of the external anal sphincter in anal incontinence. Dis Colon Rectum. May. 2004;47(5):746-52. discussion 52. Not eligible outcomes. [pmid: 15054680].
4420 Telford KJ, Faulkner G, Hosker GL, et al. The strength duration test: a novel tool in the identification of occult neuropathy in women with pelvic floor dysfunction. Colorectal Dis. Nov. 2004;6(6):442-5. Case-series. [pmid: 15521933].
4421 Telford KJ, Grey BR, MacKenzie N, et al. Investigation of stimulus position in the production of the strength duration curve of the external anal sphincter muscle in women with anorectal dysfunction. Colorectal Dis. Jan. 2007;9(1):67-70. Not eligible outcomes. [pmid: 17181848].
4422 Temml C, Heidler S, Ponholzer A, et al. Prevalence of the overactive bladder syndrome by applying the International Continence Society definition. Eur Urol. Oct. 2005;48(4):622-7. Not eligible outcomes. [pmid: 15964133].
4423 Tennstedt SL, Fitzgerald MP, Nager CW, et al. Quality of life in women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May. 2007;18(5):543-9. Case-series. [pmid: 17036169].
4424 Teo JS, Briffa NK, Devine A, et al. Do sleep problems or urinary incontinence predict falls in elderly women?. Aust J Physiother. 2006;52(1):19-24. Not eligible outcomes. [pmid: 16515419].
4425 Teo RE, Yisa S, Mayne C, et al. A comparison of urodynamic diagnoses and detrusor muscle function in white and South Indian Asian women. J Urol. Jul. 2005;174(1):184-6. Not eligible level of evidence. [pmid: 15947623].
4426 ter Meulen PH, Heesakkers JP, Janknegt RA. A study on the feasibility of vesicomyotomy in patients with motor urge incontinence. Eur Urol. 1997;32(2):166-9. Case-series. [pmid: 9286647].
4427 ter Meulen PH, Zambon V, Kessels AG, et al. Quality of life, functional outcome and durability of the AMS 800 artificial urinary sphincter in patients with intrinsic sphincter deficiency. Urol Int. 2003;71(1):55-60. Case-series. [pmid: 12845262].
4428 Ternent CA, Shashidharan M, Blatchford GJ, et al. Transanal ultrasound and anorectal physiology findings affecting continence after sphincteroplasty. Dis Colon Rectum. Apr. 1997;40(4):462-7. Case-series. [pmid: 9106697].
4429 Terra MP, Beets-Tan RG, van der Hulst VP, et al. MRI in evaluating atrophy of the external anal sphincter in patients with fecal incontinence. AJR Am J Roentgenol. Oct. 2006;187(4):991-9. Not eligible outcomes. [pmid: 16985148].
4430 Terra MP, Beets-Tan RG, van Der Hulst VP, et al. Anal sphincter defects in patients with fecal incontinence: endoanal versus external phased-array MR imaging. Radiology. Sep. 2005;236(3):886-95. Comment. [pmid: 16014438].
4431 Terra MP, Deutekom M, Beets-Tan RG, et al. Relationship between external anal sphincter atrophy at endoanal magnetic resonance imaging and clinical, functional, and anatomic characteristics in patients with fecal incontinence. Dis Colon Rectum. May. 2006;49(5):668-78. Not eligible outcomes. [pmid: 16583292].
4432 Terra MP, Dobben AC, Berghmans B, et al. Electrical stimulation and pelvic floor muscle training with biofeedback in patients with fecal incontinence: a cohort study of 281 patients. Dis Colon Rectum. Aug. 2006;49(8):1149-59. Case-series. [pmid: 16773492].
4433 Tetzschner T, Sorensen M, Jonsson L, et al. Delivery and pudendal nerve function. Acta Obstet Gynecol Scand. Apr. 1997;76(4):324-31. Not eligible outcomes. [pmid: 9174425].
4434 Tetzschner T, Sorensen M, Lose G, et al. Anal and urinary incontinence in women with obstetric anal sphincter rupture. Br J Obstet Gynaecol. Oct. 1996;103(10):1034-40. Case-series. [pmid: 8863705].
4435 Tetzschner T, Sorensen M, Rasmussen OO, et al. Pudendal nerve damage increases the risk of fecal incontinence in women with anal sphincter rupture after childbirth. Acta Obstet Gynecol Scand. Jul. 1995;74(6):434-40. Not eligible outcomes. [pmid: 7604686].
4436 Tetzschner T, Sorensen M, Rasmussen OO, et al. Reliability of pudendal nerve terminal motor latency. Int J Colorectal Dis. 1997;12(5):280-4. Not eligible outcomes. [pmid: 9401842].
4437 Teunissen D, Van Den Bosch W, Van Weel C, et al. “It can always happen”: the impact of urinary incontinence on elderly men and women. Scand J Prim Health Care. Sep. 2006;24(3):166-73. Not eligible outcomes. [pmid: 16923626].
4438 Teunissen D, van den Bosch W, van Weel C, et al. Urinary incontinence in the elderly: attitudes and experiences of general practitioners. A focus group study. Scand J Prim Health Care. Mar. 2006;24(1):56-61. Not eligible target population. [pmid: 16464816].
4439 Teunissen D, van Weel C, Lagro-Janssen T. Urinary incontinence in older people living in the community: examining help-seeking behaviour. Br J Gen Pract. Oct. 2005;55(519):776-82. Not eligible outcomes. [pmid: 16212853]. [pmcid: 1562332].
4440 Tewari A, Srivasatava A, Menon M. A prospective comparison of radical retropubic and robot-assisted prostatectomy: experience in one institution. BJU Int. Aug. 2003;92(3):205-10. Not eligible outcomes. [pmid: 12887468].
4441 Thakar R, Stanton S, Prodigalidad L, et al. Secondary colposuspension: results of a prospective study from a tertiary referral centre. Bjog. Oct. 2002;109(10):1115-20. Case-series. [pmid: 12387463].
4442 Thaler K, Dinnewitzer A, Oberwalder M, et al. Quality of life after colectomy for colonic inertia. Tech Coloproctol. Jul. 2005;9(2):133-7. Case-series. [pmid: 16007361].
4443 Theerapol A, So BY, Ngoi SS. Routine use of setons for the treatment of anal fistulae. Singapore Med J. Jun. 2002;43(6):305-7. Case-series. [pmid: 12380728].
4444 Theisen J, Kauer WK, Nekarda H, et al. Neoadjuvant radiochemotherapy for patients with locally advanced rectal cancer leads to impairment of the anal sphincter. J Gastrointest Surg. Feb. 2006;10(2):309-14. Case-series. [pmid: 16455467].
4445 Thelwell S, Symon C, Gay S, et al. Continence. Systems for leg bags. Nurs Times. Apr 19–25. 1995;91(16):62-4. Not eligible exposure. [pmid: 7731864].
4446 Themistocleous GS, Papagelopoulos PJ, Petraki KD, et al. A 23-year-old woman with complete paraplegia and anesthesia below the T8 level. Clin Orthop Relat Res 2005 Jan; (430):258–65. Case- Reports
4447 Theodoros C, Katsifotis C, Stournaras P, et al. Abdomino-perineal repair of recurrent and complex bladder neck-prostatic urethra contractures. Eur Urol. Dec. 2000;38(6):734-40. discusssion 40–1. Case-series. [pmid: 11111193].
4448 Theodorou C, Floratos D, Katsifotis C, et al. Transvaginal incisionless bladder neck suspension. A simplified technique for female genuine stress incontinence. Int Urol Nephrol. 1998;30(3):273-8. Case-series. [pmid: 9696332].
4449 Theodorou C, Moutzouris G, Floratos D, et al. Incontinence after surgery for benign prostatic hypertrophy: the case for complex approach and treatment. Eur Urol. 1998;33(4):370-5. Case-series. [pmid: 9612679].
4450 Theofrastous JP, Cundiff GW, Harris RL, et al. The effect of vesical volume on Valsalva leak-point pressures in women with genuine stress urinary incontinence. Obstet Gynecol. May. 1996;87(5 Pt 1):711-4. Not eligible outcomes. [pmid: 8677072].
4451 Thessen CC, Kreder KJ. Ogilvie's syndrome: a potential complication of vaginal surgery. J Urol. Jun. 1993;149(6):1541-3. Case Reports. [pmid: 8501808].
4452 Thiede HA, Thiede FK. A glance at the urodynamic database. J Reprod Med. Oct. 1990;35(10):925-31. Not eligible target population. [pmid: 2246758].
4453 Thiel DD, Young PR, Broderick GA, et al. Do clinical or urodynamic parameters predict artificial urinary sphincter outcome in post-radical prostatectomy incontinence?. Urology. Feb. 2007;69(2):315-9. Case-series. [pmid: 17320671].
4454 Thom DH, Nygaard IE, Calhoun EA. Urologic diseases in America project: urinary incontinence in women-national trends in hospitalizations, office visits, treatment and economic impact. J Urol. Apr. 2005;173(4):1295-301. Not eligible outcomes. [pmid: 15758785].
4455 Thomas C, Lefaucheur JP, Galula G, et al. Respective value of pudendal nerve terminal motor latency and anal sphincter electromyography in neurogenic fecal incontinence. Neurophysiol Clin. Jan. 2002;32(1):85-90. Not eligible outcomes. [pmid: 11915488].
4456 Thomas P, Ingrand P, Lalloue F, et al. Reasons of informal caregivers for institutionalizing dementia patients previously living at home: the Pixel study. Int J Geriatr Psychiatry. Feb. 2004;19(2):127-35. Not eligible outcomes. [pmid: 14758578].
4457 Thomas PJ, Nurse DE, Deliveliotis C, et al. Cystoprostatectomy and substitution cystoplasty for locally invasive bladder cancer. Br J Urol. Jul. 1992;70(1):40-2. Case-series. [pmid: 1638373].
4458 Thomas S. Investing in continence. Elder Care. Feb–Mar. 1999;11(1):32. News. [pmid: 10542509].
4459 Thomas S. Continence: an update on policy priorities and practice implications in primary care. Nurs Older People. 2001 Dec–2002 Jan;13(9):21-5. quiz 6. Comment.
4460 Thomas SH, Higham PD, Hartigan-Go K, et al. Concentration dependent cardiotoxicity of terodiline in patients treated for urinary incontinence. Br Heart J. Jul. 1995;74(1):53-6. Case-series. [pmid: 7662454]. [pmcid: 483946].
4461 Thomas WM, Jackson J, Lamont GL, et al. Early incontinence following flexible sigmoidoscopy. Br J Surg. Aug. 1990;77(8):887. Comment. [pmid: 2393810].
4462 Thomason AD, Miller JM, Delancey JO. Urinary incontinence symptoms during and after pregnancy in continent and incontinent primiparas. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2007;18(2):147-51. Not eligible level of evidence. [pmid: 16625310].
4463 Thommessen B, Bautz-Holter E, Laake K. Predictors of outcome of rehabilitation of elderly stroke patients in a geriatric ward. Clin Rehabil. Apr. 1999;13(2):123-8. Not eligible outcomes. [pmid: 10348392].
4464 Thompson AN, Levitt M. Colonic J pouch reconstruction of the radiation-damaged neorectum. Aust N Z J Surg. Aug. 2000;70(8):560-2. Case-series. [pmid: 10945547].
4465 Thompson JA, O'Sullivan PB, Briffa K, et al. Assessment of pelvic floor movement using transabdominal and transperineal ultrasound. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):285-92. Not eligible outcomes. [pmid: 15782286].
4466 Thompson JS, Quigley EM. Anal sphincteroplasty for incontinence after ileal pouch-anal anastomosis. Report of two cases. Dis Colon Rectum. Feb. 1995;38(2):215-8. Case Reports. [pmid: 7851182].
4467 Thomson A, Naidoo P, Crotty B. Bowel preparation for colonoscopy: a randomized prospective trail comparing sodium phosphate and polyethylene glycol in a predominantly elderly population. J Gastroenterol Hepatol. Feb. 1996;11(2):103-7. Not eligible outcomes. [pmid: 8672752].
4468 Thornburn P, Fader M, Dean G, et al. Improving the performance of small incontinence pads: a study of “wet comfort”. J Wound Ostomy Continence Nurs. Jul. 1997;24(4):219-25. Not eligible outcomes. [pmid: 9274279].
4469 Thornton MJ, Kennedy ML, Lubowski DZ. Extracorporeal magnetic stimulation of the pelvic floor: impact on anorectal function and physiology. A pilot study. Dis Colon Rectum. Oct. 2005;48(10):1945-50. Case-series. [pmid: 16132478].
4470 Thornton MJ, Kennedy ML, Lubowski DZ, et al. Long-term follow-up of dynamic graciloplasty for faecal incontinence. Colorectal Dis. Nov. 2004;6(6):470-6. Not eligible exposure. [pmid: 15521938].
4471 Thornton MJ, Lam A, King DW. Laparoscopic or transanal repair of rectocele? A retrospective matched cohort study. Dis Colon Rectum. Apr. 2005;48(4):792-8. Not eligible target population. [pmid: 15785902].
4472 Thornton MJ, Lam A, King DW. Bowel, bladder and sexual function in women undergoing laparoscopic posterior compartment repair in the presence of apical or anterior compartment dysfunction. Aust N Z J Obstet Gynaecol. Jun. 2005;45(3):195-200. Case-series. [pmid: 15904443].
4473 Thorp JM, Jones LH, Wells E, et al. Assessment of pelvic floor function: a series of simple tests in nulliparous women. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):94-7. Not eligible outcomes. [pmid: 8798094].
4474 Thorpe AC. How do we raise awareness and ensure the correct diagnosis and management of female urinary incontinence?. BJU Int. Jun. 2006;97(6):1141-3. Comment.
4475 Thorpe AC, Roberts JP, Williams NS, et al. Pelvic floor physiology in women with faecal incontinence and urinary symptoms. Br J Surg. Feb. 1995;82(2):173-6. Not eligible level of evidence. [pmid: 7749679].
4476 Thorpe AC, Williams NS, Badenoch DF, et al. Simultaneous dynamic electromyographic proctography and cystometrography. Br J Surg. Jan. 1993;80(1):115-20. Not eligible outcomes. [pmid: 8428268].
4477 Thunedborg P, Fischer-Rasmussen W, Jensen SB. Stress urinary incontinence and posterior bladder suspension defects. Results of vaginal repair versus Burch colposuspension. Acta Obstet Gynecol Scand. 1990;69(1):55-9. Case-series. [pmid: 2346081].
4478 Thyssen H, Lose G. New disposable vaginal device (continence guard) in the treatment of female stress incontinence. Design, efficacy and short term safety. Acta Obstet Gynecol Scand. Feb. 1996;75(2):170-3. Not eligible target population. [pmid: 8604606].
4479 Thyssen HH, Clevin L, Olesen S, et al. Urinary incontinence in elite female athletes and dancers. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(1):15-7. Question 2. [pmid: 11999199].
4480 Tiainen J, Matikainen M. Health-related quality of life after ileal J-pouch-anal anastomosis for ulcerative colitis: long-term results. Scand J Gastroenterol. Jun. 1999;34(6):601-5. Case-series. [pmid: 10440610].
4481 Tiemann D, Shea L, Klutke CG, et al. Artificial urinary sphincters. Treatment for post-prostatectomy incontinence. Aorn J 1993 Jun; 57(6):1366–72, 75–9. Case-reports
4482 Tierney JP, Robins JB, Anthony GS, et al. A costed profile audit of the surgical management of female stress incontinence. Scott Med J. Nov. 2004;49(4):133-6. Case-series. [pmid: 15648705].
4483 Tiguert R, Gheiler EL, Gudziak MR. Collagen injection in the management of post-radical prostatectomy intrinsic sphincteric deficiency. Neurourol Urodyn. 1999;18(6):653-8. Case-series. [pmid: 10529714].
4484 Tilling K, Sterne JA, Rudd AG, et al. A new method for predicting recovery after stroke. Stroke. Dec 1. 2001;32(12):2867-73. Not eligible outcomes. [pmid: 11739989].
4485 Timor-Tritsch IE, Monteagudo A, Smilen SW, et al. Simple ultrasound evaluation of the anal sphincter in female patients using a transvaginal transducer. Ultrasound Obstet Gynecol. Feb. 2005;25(2):177-83. Case-series. [pmid: 15660445].
4486 Tincello DG, Adams EJ, Richmond DH. Antenatal screening for postpartum urinary incontinence in nulliparous women: a pilot study. Eur J Obstet Gynecol Reprod Biol. Feb 10. 2002;101(1):70-3. Not eligible outcomes. [pmid: 11803103].
4487 Tincello DG, Adams EJ, Sutherst JR, et al. Oxybutynin for detrusor instability with adjuvant salivary stimulant pastilles to improve compliance: results of a multicentre, randomized controlled trial. BJU Int. Mar. 2000;85(4):416-20. Not eligible exposure. [pmid: 10691817].
4488 Tincello DG, Williams KS, Joshi M, et al. Urinary diaries: a comparison of data collected for three days versus seven days. Obstet Gynecol. Feb. 2007;109(2 Pt 1):277-80. Not eligible outcomes. [pmid: 17267824].
4489 Tinetti ME, Inouye SK, Gill TM, et al. Shared risk factors for falls, incontinence, and functional dependence. Unifying the approach to geriatric syndromes. Jama. May 3. 1995;273(17):1348-53. Not eligible level of evidence. [pmid: 7715059].
4490 Tjandra JJ, Fazio VW, Church JM, et al. Ripstein procedure is an effective treatment for rectal prolapse without constipation. Dis Colon Rectum. May. 1993;36(5):501-7. Case-series. [pmid: 8482171].
4491 Tjandra JJ, Han WR, Ooi BS, et al. Faecal incontinence after lateral internal sphincterotomy is often associated with coexisting occult sphincter defects: a study using endoanal ultrasonography. ANZ J Surg. Oct. 2001;71(10):598-602. Case-series. [pmid: 11552935].
4492 Tjandra JJ, Lubowski D. Anorectal physiological testing in Australia. ANZ J Surg. Oct. 2002;72(10):757-9. Review. [pmid: 12534392].
4493 Tjandra JJ, Milsom JW, Schroeder T, et al. Endoluminal ultrasound is preferable to electromyography in mapping anal sphincteric defects. Dis Colon Rectum. Jul. 1993;36(7):689-92. Case-series. [pmid: 8348854].
4494 Tjandra JJ, Ooi BS, Han WR. Anorectal physiologic testing for bowel dysfunction in patients with spinal cord lesions. Dis Colon Rectum. Jul. 2000;43(7):927-31. Case-series. [pmid: 10910237].
4495 Tjandra JJ, Sharma BR, McKirdy HC, et al. Anorectal physiological testing in defecatory disorders: a prospective study. Aust N Z J Surg. May. 1994;64(5):322-6. Not eligible outcomes. [pmid: 8179527].
4496 Toba K, Ouchi Y, Orimo H, et al. Urinary incontinence in elderly inpatients in Japan: a comparison between general and geriatric hospitals. Aging (Milano). Feb. 1996;8(1):47-54. Not eligible target population. [pmid: 8695676].
4497 Tobias-Machado M, Lasmar MT, Medina JJ, et al. Preliminary experience with extraperitoneal endoscopic radical prostatectomy through duplication of the open technique. Int Braz J Urol. May–Jun. 2005;31(3):228-35. Case-series. [pmid: 15992425].
4498 Tobin SA, Scott IH. Delorme operation for rectal prolapse. Br J Surg. Nov. 1994;81(11):1681-4. Case-series. [pmid: 7827907].
4499 Tocchi A, Mazzoni G, Miccini M, et al. Total lateral sphincterotomy for anal fissure. Int J Colorectal Dis. May. 2004;19(3):245-9. Case-series. [pmid: 13680282].
4500 Todd LT, Jr., Yaszemski MJ, Currier BL, et al. Bowel and bladder function after major sacral resection. Clin Orthop Relat Res 2002 Apr; (397):36–9. Case-series
4501 Toglia MR, Nolan TE. Morbidity and mortality rates of elective gynecologic surgery in the elderly woman. Am J Obstet Gynecol. Dec. 2003;189(6):1584-7. discussion 7–9. Case-series. [pmid: 14710073].
4502 Toh KL, Tan JK. Artificial urinary sphincter in adult male with neurogenic stress urinary incontinence: a rare indication. Ann Acad Med Singapore. Jun. 2005;34(5):389-90. Not eligible level of evidence. [pmid: 16021230].
4503 Tok EC, Ertunc D, Dilek U, et al. The prevalence of stress urinary incontinence among women operated on for abdominal wall hernias. Acta Obstet Gynecol Scand. Oct. 2004;83(10):962-4. Not eligible level of evidence. [pmid: 15453894].
4504 Tomita R, Igarash S, Ikeda T, et al. Defecation states in patients with or without soiling at 5 years or more after colectomy, mucosal proctectomy and ileal J pouch-anal anastomosis for ulcerative colitis. Hepatogastroenterology. Jan–Feb. 2007;54(73):58-62. Case-series. [pmid: 17419231].
4505 Tomita R, Igarashi S. Assessments of anal canal sensitivity in patients with soiling 5 years or more after colectomy, mucosal proctectomy, and ileal J pouch-anal anastomosis for ulcerative colitis. World J Surg. Jan. 2007;31(1):210-6. Case-series. [pmid: 17180565].
4506 Tomita R, Kurosu Y, Isozumi M, et al. Terminal motor latency in the pudendal nerves after colectomy with mucosal proctectomy and ileal J pouch-anal anastomosis for ulcerative colitis. Surg Today. 1995;25(2):187-9. Not eligible outcomes. [pmid: 7772927].
4507 Tomita R, Kurosu Y, Isozumi M, et al. Sacral nerve terminal motor latency after ileal J pouch-anal anastomosis for ulcerative colitis. Surg Today. 1995;25(11):946-9. Not eligible outcomes. [pmid: 8640018].
4508 Tomoe H, Kondo A, Takei M, et al. Quality of life assessments in women operated on by tension-free vaginal tape (TVT). Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):114-8. discussion 08. Case-series. [pmid: 15448883].
4509 Tomoe H, Sekiguchi Y, Horiguchi M, et al. Questionnaire survey on female urinary frequency and incontinence. Int J Urol. Jul. 2005;12(7):621-30. Not eligible outcomes. [pmid: 16045554].
4510 Tong YC. An alternative method of tension-free vaginal tape implantation for the treatment of female urinary incontinence. Urol Int. 2003;71(1):51-4. Case-series. [pmid: 12845261].
4511 Topper AK, Holliday PJ, Fernie GR. Bladder volume estimation in the elderly using a portable ultrasound-based measurement device. J Med Eng Technol. May–Jun. 1993;17(3):99-103. Not eligible outcomes. [pmid: 8263906].
4512 Torrance C, Jordan S. Bionursing: assessment of stress incontinence. Nurs Stand. Oct 18–24. 1995;10(4):29-31. Case report.
4513 Torres SA, Holley JA, Ando J, et al. Maximizing care outcomes of a patient with impaired bladder function: a PI project in a rehabilitation unit. J Nurs Care Qual. Aug. 1998;12(6):64-9. Case-series.
4514 Tosun K, Schafer G, Leonhartsberger N, et al. Treatment of severe bilateral nerve pain after Pfannenstiel incision. Urology 2006 Mar; 67(3):623 e5–6. Case Reports
4515 Tranberg KG, Moller PH. Palliation of colorectal carcinoma with the Nd-YAG laser. Eur J Surg. Jan. 1991;157(1):57-60. Case-series. [pmid: 1711379].
4516 Trezza M, Krogh K, Egekvist H, et al. Bowel problems in patients with systemic sclerosis. Scand J Gastroenterol. Apr. 1999;34(4):409-13. Case-series. [pmid: 10365902].
4517 Trieman N, Hughes J, Leff J. The TAPS Project 42: the last to leave hospital—a profile of residual long-stay populations and plans for their resettlement. Team for the Assessment of Psychiatric Services. Acta Psychiatr Scand. Nov. 1998;98(5):354-9. Not eligible level of evidence. [pmid: 9845172].
4518 Tries J. Kegel exercises enhanced by biofeedback. J Enterostomal Ther. Mar–Apr. 1990;17(2):67-76. Case-series. [pmid: 2324385].
4519 Trivalle C, Chassagne P, Bouaniche M, et al. Nosocomial febrile illness in the elderly: frequency, causes, and risk factors. Arch Intern Med. Jul 27. 1998;158(14):1560-5. Not eligible target population. [pmid: 9679797].
4520 Troeger C, Gugger M, Holzgreve W, et al. Correlation of perineal ultrasound and lateral chain urethrocystography in the anatomical evaluation of the bladder neck. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):380-4. Not eligible outcomes. [pmid: 14676997].
4521 Tromp AM, Pluijm SM, Smit JH, et al. Fall-risk screening test: a prospective study on predictors for falls in community-dwelling elderly. J Clin Epidemiol. Aug. 2001;54(8):837-44. Not eligible outcomes. [pmid: 11470394].
4522 Tromp AM, Smit JH, Deeg DJ, et al. Predictors for falls and fractures in the Longitudinal Aging Study Amsterdam. J Bone Miner Res. Dec. 1998;13(12):1932-9. Not eligible outcomes. [pmid: 9844112].
4523 Trowbridge ER, Morgan D, Trowbridge MJ, et al. Sexual function, quality of life, and severity of anal incontinence after anal sphincteroplasty. Am J Obstet Gynecol. Dec. 2006;195(6):1753-7. Case-series. [pmid: 17132478].
4524 Truijen G, Wyndaele JJ, Weyler J. Conservative treatment of stress urinary incontinence in women: who will benefit?. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(6):386-90. Case-series. [pmid: 11795642].
4525 Truss MC, Stief CG, Uckert S, et al. Initial clinical experience with the selective phosphodiesterase-I isoenzyme inhibitor vinpocetine in the treatment of urge incontinence and low compliance bladder. World J Urol. Dec. 2000;18(6):439-43. Not eligible target population. [pmid: 11204266].
4526 Tsai SJ, Lew HL, Date E, et al. Treatment of detrusor-sphincter dyssynergia by pudendal nerve block in patients with spinal cord injury. Arch Phys Med Rehabil. May. 2002;83(5):714-7. Not eligible target population. [pmid: 11994813].
4527 Tse E, Knaus R. Laparoscopic radical prostatectomy - results of 200 consecutive cases in a Canadian medical institution. Can J Urol. Apr. 2004;11(2):2172-85. Case-series. [pmid: 15182406].
4528 Tseng LH, Liang CC, Lo HP, et al. The prevalence of urinary incontinence and associated risk factors in Taiwanese women with lower urinary tract symptoms. Chang Gung Med J. Nov–Dec. 2006;29(6):596-602. Not eligible target population. [pmid: 17302224].
4529 Tseng LH, Lo TS, Wang AC, et al. Bladder perforation presenting as vulvar edema after the tension-free vaginal tape procedure. A case report. J Reprod Med. Oct. 2003;48(10):824-6. Not eligible exposure. [pmid: 14619653].
4530 Tsiaoussis J, Chrysos E, Athanasakis E, et al. Rectoanal intussusception: presentation of the disorder and late results of resection rectopexy. Dis Colon Rectum. Apr. 2005;48(4):838-44. Not eligible exposure. [pmid: 15747074].
4531 Tsivian A, Kessler O, Mogutin B, et al. Tape related complications of the tension-free vaginal tape procedure. J Urol. Feb. 2004;171(2 Pt 1):762-4. Not eligible target population. [pmid: 14713805].
4532 Tsivian A, Shtricker A, Levin S, et al. Bone anchor 4-corner cystourethropexy: long-term results. J Urol. Jun. 2003;169(6):2244-5. Case-series. [pmid: 12771760].
4533 Tsugawa C, Hisano K, Nishijima E, et al. Posterior sagittal anorectoplasty for failed imperforate anus surgery: lessons learned from secondary repairs. J Pediatr Surg. Nov. 2000;35(11):1626-9. Not eligible target population. [pmid: 11083438].
4534 Tsui KP, Ng SC, Tee YT, et al. Complications of synthetic graft materials used in suburethral sling procedures. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):165-7. Case Reports. [pmid: 15789150].
4535 Tsui KP, Ng SC, Yeh GP, et al. Changes of urethral pressure profilometry in pubovaginal sling and modified Burch colposuspension procedures. Taiwan J Obstet Gynecol. Jun. 2006;45(2):129-34. Case-series. [pmid: 17197353].
4536 Tsujimura A, Matsumiya K, Miyagawa Y, et al. Relation between erectile dysfunction and urinary incontinence after nerve-sparing and non-nerve-sparing radical prostatectomy. Urol Int. 2004;73(1):31-5. Case-series. [pmid: 15263790].
4537 Tsunoda A, Shibusawa M, Kamiyama G, et al. The effect of vaginal delivery on the pelvic floor. Surg Today. 1999;29(12):1243-7. Not eligible outcomes. [pmid: 10639704].
4538 Tsunoda A, Yasuda N, Yokoyama N, et al. Delorme's procedure for rectal prolapse: clinical and physiological analysis. Dis Colon Rectum. Sep. 2003;46(9):1260-5. Case-series. [pmid: 12972972].
4539 Tuckson WB, Fazio VW. Functional comparison between double and triple ileal loop pouches. Dis Colon Rectum. Jan. 1991;34(1):17-21. Case-series. [pmid: 1846798].
4540 Tulchinsky H, McCourtney JS, Rao KV, et al. Salvage abdominal surgery in patients with a retained rectal stump after restorative proctocolectomy and stapled anastomosis. Br J Surg. Dec. 2001;88(12):1602-6. Case-series. [pmid: 11736972].
4541 Tulikangas PK, Weber AM, Larive AB, et al. Intraoperative cystoscopy in conjunction with anti-incontinence surgery. Obstet Gynecol. Jun. 2000;95(6 Pt 1):794-6. Not eligible exposure. [pmid: 10831968].
4542 Tunn R, DeLancey JO, Howard D, et al. MR imaging of levator ani muscle recovery following vaginal delivery. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(5):300-7. Not eligible exposure. [pmid: 10543338].
4543 Tunn R, Goldammer K, Gauruder-Burmester A, et al. Pathogenesis of urethral funneling in women with stress urinary incontinence assessed by introital ultrasound. Ultrasound Obstet Gynecol. Sep. 2005;26(3):287-92. Case-series. [pmid: 16082725].
4544 Tunn R, Goldammer K, Neymeyer J, et al. MRI morphology of the levator ani muscle, endopelvic fascia, and urethra in women with stress urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Jun 1. 2006;126(2):239-45. Case-series. [pmid: 16298035].
4545 Tunn R, Paris S, Fischer W, et al. Static magnetic resonance imaging of the pelvic floor muscle morphology in women with stress urinary incontinence and pelvic prolapse. Neurourol Urodyn. 1998;17(6):579-89. Not eligible outcomes. [pmid: 9829422].
4546 Tunn R, Rieprich M, Kaufmann O, et al. Morphology of the suburethral pubocervical fascia in women with stress urinary incontinence: a comparison of histologic and MRI findings. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):480-6. Not eligible outcomes. [pmid: 16034512].
4547 Tunuguntla HS, Gousse AE. Missed bilateral bladder perforation during pubovaginal sling procedure. J Urol. Jul. 2004;172(1):189-90. Case Reports. [pmid: 15201769].
4548 Tur BS, Suldur N, Ataman S, et al. Brucellar spondylitis: a rare cause of spinal cord compression. Spinal Cord. May. 2004;42(5):321-4. Case- Reports. [pmid: 15123999].
4549 Turkan A, Inci Y, Fazli D. The short-term effects of physical therapy in different intensities of urodynamic stress incontinence. Gynecol Obstet Invest. 2005;59(1):43-8. Case-series. [pmid: 15459518].
4550 Turner T. Continence. Muscle control. Nurs Times. Mar 9–15. 1994;90(10):64-9. Comment. [pmid: 8152961].
4551 Turner WH, Danuser H, Moehrle K, et al. The effect of nerve sparing cystectomy technique on postoperative continence after orthotopic bladder substitution. J Urol. Dec. 1997;158(6):2118-22. Case-series. [pmid: 9366326].
4552 Turner-Stokes L, L AO. Urinary incontinence among patients with arthritis—a neglected disability. J R Soc Med. Jul. 1992;85(7):389-93. Not eligible level of evidence. [pmid: 1629846]. [pmcid: 1293544].
4553 Tutuarima JA, van der Meulen JH, de Haan RJ, et al. Risk factors for falls of hospitalized stroke patients. Stroke. Feb. 1997;28(2):297-301. Not eligible outcomes. [pmid: 9040678].
4554 Tuygun C, Imamoglu A, Keyik B, et al. Significance of fibrosis around and/or at external urinary sphincter on pelvic magnetic resonance imaging in patients with postprostatectomy incontinence. Urology. Dec. 2006;68(6):1308-12. Not eligible outcomes. [pmid: 17169652].
4555 Twiss C, Fleischmann N, Nitti VW. Correlation of abdominal leak point pressure with objective incontinence severity in men with post-radical prostatectomy stress incontinence. Neurourol Urodyn. 2005;24(3):207-10. Case-series. [pmid: 15791628].
4556 Uchiyama T, Sakakibara R, Hattori T, et al. Short-term effect of a single levodopa dose on micturition disturbance in Parkinson's disease patients with the wearing-off phenomenon. Mov Disord. May. 2003;18(5):573-8. Not eligible target population. [pmid: 12722172].
4557 Ullrich NF, Comiter CV. The male sling for stress urinary incontinence: 24-month followup with questionnaire based assessment. J Urol. Jul. 2004;172(1):207-9. Case-series. [pmid: 15201775].
4558 Ullrich NF, Comiter CV. The male sling for stress urinary incontinence: urodynamic and subjective assessment. J Urol. Jul. 2004;172(1):204-6. Case-series. [pmid: 15201774].
4559 Ulmsten U, Falconer C, Johnson P, et al. A multicenter study of tension-free vaginal tape (TVT) for surgical treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(4):210-3. Not eligible target population. [pmid: 9795826].
4560 Ulmsten U, Henriksson L, Johnson P, et al. An ambulatory surgical procedure under local anesthesia for treatment of female urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):81-5. discussion 5–6. Not eligible exposure. [pmid: 8798092].
4561 Ulmsten U, Johnson P, Rezapour M. A three-year follow up of tension free vaginal tape for surgical treatment of female stress urinary incontinence. Br J Obstet Gynaecol. Apr. 1999;106(4):345-50. Not eligible target population. [pmid: 10426241].
4562 Ulmsten U, Petros P. Intravaginal slingplasty (IVS): an ambulatory surgical procedure for treatment of female urinary incontinence. Scand J Urol Nephrol. Mar. 1995;29(1):75-82. Not eligible target population. [pmid: 7618052].
4563 Ulrich A, Z'Graggen K, Weitz J, et al. Functional results of the colon J-pouch versus transverse coloplasty pouch in Heidelberg. Recent Results Cancer Res. 2005;165:205-11. No associative hypothesis testes. [pmid: 15865035].
4564 Uludag O, Koch SM, Dejong CH, et al. Sacral neuromodulation; does it affect colonic transit time in patients with faecal incontinence?. Colorectal Dis. May. 2006;8(4):318-22. Not eligible target population. [pmid: 16630237].
4565 Uludag O, Koch SM, van Gemert WG, et al. Sacral neuromodulation in patients with fecal incontinence: a single-center study. Dis Colon Rectum. Aug. 2004;47(8):1350-7. Not eligible target population. [pmid: 15484349].
4566 Uludag O, Morren GL, Dejong CH, et al. Effect of sacral neuromodulation on the rectum. Br J Surg. Aug. 2005;92(8):1017-23. Case-series. [pmid: 15997445].
4567 Uma R, Libby G, Murphy DJ. Obstetric management of a woman's first delivery and the implications for pelvic floor surgery in later life. Bjog. Aug. 2005;112(8):1043-6. Not eligible outcomes. [pmid: 16045515].
4568 Umstad MP, Glenning PP. Urodynamic investigation in the management of incontinent women. Asia Oceania J Obstet Gynaecol. Dec. 1991;17(4):307-13. Case-series. [pmid: 1801676].
4569 Unterweger M, Marincek B, Gottstein-Aalame N, et al. Ultrafast MR imaging of the pelvic floor. AJR Am J Roentgenol. Apr. 2001;176(4):959-63. Case-series. [pmid: 11264088].
4570 Upton N, Reed V. The meaning of incontinence in dementia care. Int J Psychiatr Nurs Res. Sep. 2005;11(1):1200-10. Not eligible outcomes. [pmid: 16268229].
4571 Urso E, Serpentini S, Pucciarelli S, et al. Complications, functional outcome and quality of life after intensive preoperative chemoradiotherapy for rectal cancer. Eur J Surg Oncol. Dec. 2006;32(10):1201-8. No associative hypothesis tested. [pmid: 16872799].
4572 Ushiroyama T, Ikeda A, Ueki M. Prevalence, incidence, and awareness in the treatment of menopausal urinary incontinence. Maturitas. Oct 24. 1999;33(2):127-32. Not eligible level of evidence. [pmid: 10597876].
4573 Ushiroyama T, Ikeda A, Ueki M. Clinical efficacy of clenbuterol and propiverine in menopausal women with urinary incontinence: improvement in quality of life. J Med. 2000;31(56):311-9. Not eligible target population. [pmid: 11508324].
4574 Ustun Y, Engin-Ustun Y, Gungor M, et al. Randomized comparison of Burch urethropexy procedures concomitant with gynecologic operations. Gynecol Obstet Invest. 2005;59(1):19-23. Not eligible exposure. [pmid: 15627777].
4575 Vaccaro CA, Cheong DM, Wexner SD, et al. Pudendal neuropathy in evacuatory disorders. Dis Colon Rectum. Feb. 1995;38(2):166-71. Not eligible outcomes. [pmid: 7851171].
4576 Vaidya A, Soloway MS. Salvage radical prostatectomy for radiorecurrent prostate cancer: morbidity revisited. J Urol. Dec. 2000;164(6):1998-2001. Case-series. [pmid: 11061900].
4577 Vaidyananthan S, Soni BM, Brown E, et al. Effect of intermittent urethral catheterization and oxybutynin bladder instillation on urinary continence status and quality of life in a selected group of spinal cord injury patients with neuropathic bladder dysfunction. Spinal Cord. Jun. 1998;36(6):409-14. Not eligible target population. [pmid: 9648197].
4578 Vaidyanathan S, Soni BM, Sett P, et al. Flawed trial of micturition in cervical spinal cord injury patients: guidelines for trial of voiding in men with tetraplegia. Spinal Cord. Dec. 2003;41(12):667-72. Case-series. [pmid: 14639445].
4579 Vaizey CJ, Carapeti E, Cahill JA, et al. Prospective comparison of faecal incontinence grading systems. Gut. Jan. 1999;44(1):77-80. Case-series. [pmid: 9862829]. [pmcid: 1760067].
4580 Vaizey CJ, Kamm MA. Prospective assessment of the clinical value of anorectal investigations. Digestion. 2000;61(3):207-14. Not eligible outcomes. [pmid: 10773727].
4581 Vaizey CJ, Kamm MA, Bartram CI. Primary degeneration of the internal anal sphincter as a cause of passive faecal incontinence. Lancet. Mar 1. 1997;349(9052):612-5. Not eligible outcomes. [pmid: 9057734].
4582 Vaizey CJ, Kamm MA, Gold DM, et al. Clinical, physiological, and radiological study of a new purpose-designed artificial bowel sphincter. Lancet. Jul 11. 1998;352(9122):105-9. Case-series. [pmid: 9672276].
4583 Vaizey CJ, Kamm MA, Roy AJ, et al. Double-blind crossover study of sacral nerve stimulation for fecal incontinence. Dis Colon Rectum. Mar. 2000;43(3):298-302. Not eligible target population. [pmid: 10733109].
4584 Vaizey CJ, Kamm MA, Turner IC, et al. Effects of short term sacral nerve stimulation on anal and rectal function in patients with anal incontinence. Gut. Mar. 1999;44(3):407-12. Case-series. [pmid: 10026329]. [pmcid: 1727421].
4585 Vaizey CJ, Norton C, Thornton MJ, et al. Long-term results of repeat anterior anal sphincter repair. Dis Colon Rectum. Jun. 2004;47(6):858-63. Case-series. [pmid: 15129307].
4586 Vajda P, Buyukunal CS, Soylet Y, et al. A therapeutic method for failed bladder augmentation in children: re-augmentation. BJU Int. Apr. 2006;97(4):816-9. discussion 9. Not eligible target population. [pmid: 16536781].
4587 Valappil SV, Nan A. Successful treatment of persistent voiding dysfunction following Tension Free Vaginal Tape procedure. J Obstet Gynaecol. Jan. 2005;25(1):79. Case Reports. [pmid: 16147710].
4588 Valiquette L, Duclos AJ, Lapointe SP. FPSUND: a new clinical classification of urinary incontinence. Can J Urol. Jun. 2000;7(3):1038-42. Not eligible outcomes. [pmid: 11118279].
4589 Valk M, Post MW, Cools HJ, et al. Measuring disability in nursing home residents: validity and reliability of a newly developed instrument. J Gerontol B Psychol Sci Soc Sci. May. 2001;56(3):P187-91. Not eligible outcomes. [pmid: 11316837].
4590 Valldeoriola F, Valls-Sole J, Tolosa ES, et al. Striated anal sphincter denervation in patients with progressive supranuclear palsy. Mov Disord. Sep. 1995;10(5):550-5. Not eligible exposure. [pmid: 8552104].
4591 Valvanne J, Juva K, Erkinjuntti T, et al. Major depression in the elderly: a population study in Helsinki. Int Psychogeriatr. Fall. 1996;8(3):437-43. Not eligible outcomes. [pmid: 9116179].
4592 Van Andel G, Visser AP, Hulshof MC, et al. Health-related quality of life and psychosocial factors in patients with prostate cancer scheduled for radical prostatectomy or external radiation therapy. BJU Int. Aug. 2003;92(3):217-22. Case-series. [pmid: 12887470].
4593 van Andel G, Visser AP, Zwinderman AH, et al. A prospective longitudinal study comparing the impact of external radiation therapy with radical prostatectomy on health related quality of life (HRQOL) in prostate cancer patients. Prostate. Mar 1. 2004;58(4):354-65. Case series. [pmid: 14968436].
4594 van Balken MR, Vergunst H, Bemelmans BL. Sexual functioning in patients with lower urinary tract dysfunction improves after percutaneous tibial nerve stimulation. Int J Impot Res. Sep–Oct. 2006;18(5):470-5. discussion 6. Not eligible target population. [pmid: 16528293].
4595 van Balken MR, Vergunst H, Bemelmans BL. Prognostic factors for successful percutaneous tibial nerve stimulation. Eur Urol. Feb. 2006;49(2):360-5. Not eligible target population. [pmid: 16359781].
4596 van Bennekom CA, Jelles F, Lankhorst GJ, et al. The Rehabilitation Activities Profile: a validation study of its use as a disability index with stroke patients. Arch Phys Med Rehabil. Jun. 1995;76(6):501-7. Not eligible outcomes. [pmid: 7763147].
4597 Van Brummen HJ, Bruinse HW, Van de Pol G, et al. What is the effect of overactive bladder symptoms on woman's quality of life during and after first pregnancy?. BJU Int. Feb. 2006;97(2):296-300. Not eligible outcomes. [pmid: 16430633].
4598 van Brummen HJ, van de Pol G, Aalders CI, et al. Sacrospinous hysteropexy compared to vaginal hysterectomy as primary surgical treatment for a descensus uteri: effects on urinary symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):350-5. discussion 5. Case-series. [pmid: 14618315].
4599 van Dam JH, Huisman WM, Hop WC, et al. Fecal continence after rectocele repair: a prospective study. Int J Colorectal Dis. Feb. 2000;15(1):54-7. Case-series. [pmid: 10766092].
4600 van de Port IG, Kwakkel G, Schepers VP, et al. Predicting mobility outcome one year after stroke: a prospective cohort study. J Rehabil Med. Jul. 2006;38(4):218-23. Not eligible outcomes. [pmid: 16801203].
4601 van der Hagen SJ, van Gemert WG, Baeten CG. PTQ Implants in the treatment of faecal soiling. Br J Surg. Feb. 2007;94(2):222-3. Case-series. [pmid: 17205492].
4602 van der Hurk PR, Middelkoop HA, van Waalwijk-van Doorn ES, et al. Long-term ambulatory monitoring of urine leakage in the elderly: an evaluation of the validity and clinical applicability of thermistor signalling. J Med Eng Technol. Mar–Apr. 1998;22(2):91-3. Case-reports. [pmid: 9597581].
4603 van der Linden MC, Gerretsen G, Brandhorst MS, et al. The effect of estriol on the cytology of urethra and vagina in postmenopausal women with genito-urinary symptoms. Eur J Obstet Gynecol Reprod Biol. Sep. 1993;51(1):29-33. Not eligible outcomes. [pmid: 8282140].
4604 van der Pal F, van Balken MR, Heesakkers JP, et al. Percutaneous tibial nerve stimulation in the treatment of refractory overactive bladder syndrome: is maintenance treatment necessary?. BJU Int. Mar. 2006;97(3):547-50. Not eligible target population. [pmid: 16469023].
4605 van der Vaart CH, de Leeuw JR, Roovers JP, et al. Measuring health-related quality of life in women with urogenital dysfunction: the urogenital distress inventory and incontinence impact questionnaire revisited. Neurourol Urodyn. 2003;22(2):97-104. Not eligible outcomes. [pmid: 12579625].
4606 van der Weide M, Smits J. Adoption of innovations by specialised nurses: personal, work and organisational characteristics. Health Policy. Apr. 2004;68(1):81-92. Not eligible exposure. [pmid: 15033555].
4607 van Dijk MM, Mochtar CA, Wijkstra H, et al. The bell-shaped nitinol prostatic stent in the treatment of lower urinary tract symptoms: experience in 108 patients. Eur Urol. Feb. 2006;49(2):353-9. Case-series. [pmid: 16426738].
4608 van Duijvendijk P, Slors F, Taat CW, et al. A prospective evaluation of anorectal function after total mesorectal excision in patients with a rectal carcinoma. Surgery. Jan. 2003;133(1):56-65. Not eligible exposure. [pmid: 12563238].
4609 van Eijken M, Wensing M, de Konink M, et al. Health education on self-management and seeking health care in older adults: a randomised trial. Patient Educ Couns. Oct. 2004;55(1):48-54. Not eligible outcomes. [pmid: 15476989].
4610 van Geelen JM, van de Weijer PH, Arnolds HT. Urogenital symptoms and resulting discomfort in non-institutionalized Dutch women aged 50–75 years. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(1):9-14. Not eligible level of evidence. [pmid: 10738928].
4611 Van Gossum A, Zalcman M, Adler M, et al. Anorectal stenosis in patients with prolonged use of suppositories containing paracetamol and acetylsalicylic acid. Dig Dis Sci. Nov. 1993;38(11):1970-7. Case-reports. [pmid: 8223068].
4612 Van Kampen M, De Weerdt W, Van Poppel H, et al. Prediction of urinary continence following radical prostatectomy. Urol Int. 1998;60(2):80-4. Not eligible level of evidence. [pmid: 9563144].
4613 Van Kerrebroeck EV, van der Aa HE, Bosch JL, et al. Sacral rhizotomies and electrical bladder stimulation in spinal cord injury. Part I: Clinical and urodynamic analysis. Dutch Study Group on Sacral Anterior Root Stimulation. Eur Urol. 1997;31(3):263-71. Not eligible target population. [pmid: 9129914].
4614 van Kerrebroeck P, Abrams P, Lange R, et al. Duloxetine versus placebo in the treatment of European and Canadian women with stress urinary incontinence. BJOG. Mar. 2004;111(3):249-57. Not eligible exposure. [pmid: 14961887].
4615 Van Kerrebroeck P, Kreder K, Jonas U, et al. Tolterodine once-daily: superior efficacy and tolerability in the treatment of the overactive bladder. Urology. Mar. 2001;57(3):414-21. Not eligible exposure. [pmid: 11248608].
4616 van Kerrebroeck P, ter Meulen F, Larsson G, et al. Treatment of stress urinary incontinence using a copolymer system: impact on quality of life. BJU Int. Nov. 2004;94(7):1040-3. Not eligible target population. [pmid: 15541124].
4617 Van Kerrebroeck PE, Koldewijn EL, Debruyne FM. Worldwide experience with the Finetech-Brindley sacral anterior root stimulator. Neurourol Urodyn. 1993;12(5):497-503. Review. [pmid: 8252057].
4618 van Laarhoven CJ, Andriesse GI, Schipper ME, et al. Ileoneorectal anastomosis: early clinical results of a restorative procedure for ulcerative colitis and familial adenomatous polyposis without formation of an ileoanal pouch. Ann Surg. Dec. 1999;230(6):750-7. discussion 7–8. Case-series. [pmid: 10615929]. [pmcid: 1420938].
4619 van Melick HH, Gisolf KW, Eckhardt MD, et al. One 24-hour frequency-volume chart in a woman with objective urinary motor urge incontinence is sufficient. Urology. Aug. 2001;58(2):188-92. Case-series. [pmid: 11489695].
4620 van Os-Bossagh P, Pols T, Hop WC, et al. Voiding symptoms in chronic pelvic pain (CPP). Eur J Obstet Gynecol Reprod Biol. Apr 25. 2003;107(2):185-90. Case-series. [pmid: 12648866].
4621 Van Rijswijk L. AHCPR update. The guidelines for urinary incontinence in adults. Ostomy Wound Manage. May. 1992;38(4):8-10. Guideline. [pmid: 1590909].
4622 Van Savage JG, Chancellor MB, Slaughenhoupt B. Transverse retubularized ileovesicostomy continent urinary diversion to the umbilicus. Tech Urol. Mar. 2000;6(1):29-33. Case-series. [pmid: 10708145].
4623 Van Savage JG, Khoury AE, McLorie GA, et al. Outcome analysis of Mitrofanoff principle applications using appendix and ureter to umbilical and lower quadrant stomal sites. J Urol. Nov. 1996;156(5):1794-7. Not eligible target population. [pmid: 8863618].
4624 Van Savage JG, Yepuri JN. Transverse retubularized sigmoidovesicostomy continent urinary diversion to the umbilicus. J Urol. Aug. 2001;166(2):644-7. Not eligible target population. [pmid: 11458110].
4625 Van Savage JG, Yohannes P. Laparoscopic antegrade continence enema in situ appendix procedure for refractory constipation and overflow fecal incontinence in children with spina bifida. J Urol. Sep. 2000;164(3 Pt 2):1084-7. Not eligible target population. [pmid: 10958747].
4626 van Straaten EC, Fazekas F, Rostrup E, et al. Impact of white matter hyperintensities scoring method on correlations with clinical data: the LADIS study. Stroke. Mar. 2006;37(3):836-40. Not eligible outcomes. [pmid: 16439704].
4627 Van Tets WF, Kuijpers JH. Seton treatment of perianal fistula with high anal or rectal opening. Br J Surg. Jul. 1995;82(7):895-7. Case-series. [pmid: 7648099].
4628 van Tets WF, Kuijpers JH, Bleijenberg G. Biofeedback treatment is ineffective in neurogenic fecal incontinence. Dis Colon Rectum. Sep. 1996;39(9):992-4. Case-series. [pmid: 8797647].
4629 Van Tets WF, Kuijpers JH, Mortelmans LJ, et al. Sphincter-saving surgery for rectal and colorectal disorders. Scand J Gastroenterol Suppl. 1996;218:34-7. Case-series. [pmid: 8865448].
4630 van Venrooij GE, Boon TA. Extensive urodynamic investigation: interaction among diuresis, detrusor instability, urethral relaxation, incontinence and complaints in women with a history of urge incontinence. J Urol. Nov. 1994;152(5 Pt 1):1535-8. Not eligible exposure. [pmid: 7933194].
4631 van Voskuilen AC, Oerlemans DJ, Weil EH, et al. Long term results of neuromodulation by sacral nerve stimulation for lower urinary tract symptoms: a retrospective single center study. Eur Urol. Feb. 2006;49(2):366-72. Not eligible outcomes. [pmid: 16413105].
4632 van Waalwijk van Doorn ES, Remmers A, Janknegt RA. Extramural ambulatory urodynamic monitoring during natural filling and normal daily activities: evaluation of 100 patients. J Urol. Jul. 1991;146(1):124-31. Not eligible outcomes. [pmid: 2056570].
4633 Van Zak DB. Non-invasive feedback of external pubococcegii muscle activity as a treatment for urinary incontinence. Int J Psychosom. 1993;40(14):56-9. Case-series. [pmid: 8070987].
4634 van Zon-Rabelink I, Laven J, Vleugels M. The bacteriological changes after re-using a vaginal continence guard. Acta Obstet Gynecol Scand. Sep. 1999;78(8):722-7. Case-series. [pmid: 10468066].
4635 Vandoninck V, Van Balken MR, Finazzi Agro E, et al. Posterior tibial nerve stimulation in the treatment of urge incontinence. Neurourol Urodyn. 2003;22(1):17-23. Not eligible target population. [pmid: 12478596].
4636 Vandoninck V, van Balken MR, Finazzi Agro E, et al. Percutaneous tibial nerve stimulation in the treatment of overactive bladder: urodynamic data. Neurourol Urodyn. 2003;22(3):227-32. Not eligible target population. [pmid: 12707873].
4637 Varkarakis J, Pinggera GM, Sebe P, et al. Radical retropubic prostatectomy in men younger than 45 years diagnosed during early prostate cancer detection program. Urology. Feb. 2004;63(2):337-41. Not eligible outcomes. [pmid: 14972485].
4638 Varma A, Gunn J, Gardiner A, et al. Obstetric anal sphincter injury: prospective evaluation of incidence. Dis Colon Rectum. Dec. 1999;42(12):1537-43. Not eligible outcomes. [pmid: 10613471].
4639 Varma A, Gunn J, Lindow SW, et al. Do routinely measured delivery variables predict anal sphincter outcome?. Dis Colon Rectum. Oct. 1999;42(10):1261-4. Not eligible outcomes. [pmid: 10528761].
4640 Varma JS. Autonomic influences on colorectal motility and pelvic surgery. World J Surg. Sep–Oct. 1992;16(5):811-9. Case-series. [pmid: 1462613].
4641 Varner RE, Plessala KJ, Richter H. Effects of sacrocolposuspension on the lower urinary tract. Am J Obstet Gynecol. Dec. 1995;173(6):1684-8. discussion 8–9. Case-series. [pmid: 8610745].
4642 Vaseemuddin M, Sam R. Large B-cell non-Hodgkin lymphoma. Am J Kidney Dis 2005 Dec; 46(6):A52, e101–2. Case- Reports
4643 Vassallo BJ, Kleeman SD, Segal J, et al. Urethral erosion of a tension-free vaginal tape. Obstet Gynecol. May. 2003;101(5 Pt 2):1055-8. Case Reports. [pmid: 12738099].
4644 Vassallo BJ, Kleeman SD, Segal JL, et al. Tension-free vaginal tape: a quality-of-life assessment. Obstet Gynecol. Sep. 2002;100(3):518-24. Not eligible exposure. [pmid: 12220772].
4645 Vassilakis JS, Pechlivanides G, Zoras OJ, et al. Anorectal function after low anterior resection of the rectum. Int J Colorectal Dis. 1995;10(2):101-6. Case-series. [pmid: 7636368].
4646 Vazzoler N, Soulie M, Escourrou G, et al. Pubourethral ligaments in women: anatomical and clinical aspects. Surg Radiol Anat. Feb. 2002;24(1):33-7. Not eligible target population. [pmid: 12197008].
4647 Vecchioli Scaldazza C. Rehabilitative treatment of non-neurogenic female urinary incontinence. Clinical and urodynamic evaluation. Minerva Urol Nefrol. Mar. 1997;49(1):5-8. Not eligible target population. [pmid: 9099056].
4648 Vegh A. Two methods in the treatment of prostate cancer T1–T2. Acta Chir Hung. 1997;36(14):383-5. Case-series. [pmid: 9408411].
4649 Vehmas T, Lindell O, Soimakallio S, et al. Percutaneous nephrostomy in the management of urinary leakages and fistulas. Rontgenblatter. Dec. 1990;43(12):512-5. Case-series. [pmid: 2287880].
4650 Velez JB. Behavior therapy for urge incontinence in older women. J Fam Pract. Mar. 1999;48(3):168-9. News. [pmid: 10086751].
4651 Venkatesan P, Gladman J, Macfarlane JT, et al. A hospital study of community acquired pneumonia in the elderly. Thorax. Apr. 1990;45(4):254-8. Case-series. [pmid: 2356552]. [pmcid: 473766].
4652 Venkatesh KS, Ramanujam P. Surgical treatment of traumatic cloaca. Dis Colon Rectum. Jul. 1996;39(7):811-6. Case-series. [pmid: 8674376].
4653 Vereecken RL, Van Nuland T. Detrusor pressure in ambulatory versus standard urodynamics. Neurourol Urodyn. 1998;17(2):129-33. Case-series. [pmid: 9514145].
4654 Verelst M, Maltau JM, Orbo A. Computerised morphometric study of the paraurethral tissue in young and elderly women. Neurourol Urodyn. 2002;21(6):529-33. Not eligible outcomes. [pmid: 12382242].
4655 Verhoef M, Barf HA, Post MW, et al. Functional independence among young adults with spina bifida, in relation to hydrocephalus and level of lesion. Dev Med Child Neurol. Feb. 2006;48(2):114-9. Not eligible target population. [pmid: 16417666].
4656 Verhoef M, Lurvink M, Barf HA, et al. High prevalence of incontinence among young adults with spina bifida: description, prediction and problem perception. Spinal Cord. Jun. 2005;43(6):331-40. Not eligible target population. [pmid: 15685262].
4657 Vernava AM 3rd, Longo WE, Daniel GL. Pudendal neuropathy and the importance of EMG evaluation of fecal incontinence. Dis Colon Rectum. Jan. 1993;36(1):23-7. Case-series. [pmid: 8380139].
4658 Vernon S, Bleakley S. A successful bladder retraining program. Nurs Times. Sep 17–23. 1997;93(38):50-1. Case Reports. [pmid: 9362908].
4659 Vernon T. Managing excoriation. Nurs Times. Jul 20. 2000;96(29 Suppl):12. Case Reports. [pmid: 11963705].
4660 Veronikis DK, Nichols DH, Spino C. The Noble-Mengert-Fish operation-revisited: a composite approach for persistent rectovaginal fistulas and complex perineal defects. Am J Obstet Gynecol. Dec. 1998;179(6 Pt 1):1411-6. discussion 6–7. Case-series. [pmid: 9855574].
4661 Veronikis DK, Nichols DH, Wakamatsu MM. The incidence of low-pressure urethra as a function of prolapse-reducing technique in patients with massive pelvic organ prolapse (maximum descent at all vaginal sites). Am J Obstet Gynecol. Dec. 1997;177(6):1305-13. discussion 13–4. Not eligible level of evidence. [pmid: 9423729].
4662 Versi E. Incontinence in the climacteric. Clin Obstet Gynecol. Jun. 1990;33(2):392-8. Review. [pmid: 2350922].
4663 Versi E, Appell R, Mobley D, et al. Dry mouth with conventional and controlled-release oxybutynin in urinary incontinence. The Ditropan XL Study Group. Obstet Gynecol. May. 2000;95(5):718-21. Not eligible exposure. [pmid: 10775736].
4664 Versi E, Griffiths DJ, Harvey MA. A new external urethral occlusive device for female urinary incontinence. Obstet Gynecol. Aug. 1998;92(2):286-91. Not eligible target population. [pmid: 9699768].
4665 Versi E, Harvey MA. Efficacy of an external urethral device in women with genuine stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(5):271-4. Not eligible target population. [pmid: 9849759].
4666 Versi E, Lyell DJ, Griffiths DJ. Videourodynamic diagnosis of occult genuine stress incontinence in patients with anterior vaginal wall relaxation. J Soc Gynecol Investig. Nov–Dec. 1998;5(6):327-30. Case-series.
4667 Versluis PJ, Konsten J, Geerdes B, et al. Defecographic evaluation of dynamic graciloplasty for fecal incontinence. Dis Colon Rectum. May. 1995;38(5):468-73. Case-series. [pmid: 7736876].
4668 Vgontzas AN, Sollenberger SE, Kales A, et al. Narcolepsy-cataplexy and loss of sphincter control. Postgrad Med J. Aug. 1996;72(850):493-4. Case- Reports. [pmid: 8796217]. [pmcid: 2398551].
4669 Vicini FA, Kestin LL, Martinez AA. Use of conformal high-dose rate brachytherapy for management of patients with prostate cancer: optimizing dose escalation. Tech Urol. Jun. 2000;6(2):135-45. Not eligible outcomes. [pmid: 10798815].
4670 Vickerman J. Environmental problems: valuable equipment. Nurs Times. Apr 23–29. 2002;98(17):57. Comment. [pmid: 12008268].
4671 Videla FL, Wall LL. Stress incontinence diagnosed without multichannel urodynamic studies. Obstet Gynecol. Jun. 1998;91(6):965-8. Not eligible outcomes. [pmid: 9611005].
4672 Viereck V, Bader W, Krauss T, et al. Intra-operative introital ultrasound in Burch colposuspension reduces post-operative complications. Bjog. Jun. 2005;112(6):791-6. Case-series. [pmid: 15924539].
4673 Viereck V, Bader W, Skala C, et al. Determination of bladder neck position by intraoperative introital ultrasound in colposuspension: outcome at 6-month follow-up. Ultrasound Obstet Gynecol. Aug. 2004;24(2):186-91. Case-series. [pmid: 15287058].
4674 Viereck V, Pauer HU, Bader W, et al. Introital ultrasound of the lower genital tract before and after colposuspension: a 4-year objective follow-up. Ultrasound Obstet Gynecol. Mar. 2004;23(3):277-83. Not eligible target population. [pmid: 15027018].
4675 Vierhout ME. Severe hemorrhage complicating tension-free vaginal tape (TVT): a case report. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):139-40. Case Reports. [pmid: 11374513].
4676 Vierhout ME, Gianotten WL. Mechanisms of urine loss during sexual activity. Eur J Obstet Gynecol Reprod Biol. Nov. 1993;52(1):45-7. Not eligible outcomes. [pmid: 8119474].
4677 Vierhout ME, Hol M. Vaginal ultrasound studies before and after successful colposuspension and in continent controls. Acta Obstet Gynecol Scand. Jan. 1998;77(1):101-4. Not eligible oucomes. [pmid: 9492728].
4678 Vigod SN, Stewart DE. Major depression in female urinary incontinence. Psychosomatics. Mar–Apr. 2006;47(2):147-51. Not eligible outcomes. [pmid: 16508027].
4679 Viktrup L, Lose G. Epidural anesthesia during labor and stress incontinence after delivery. Obstet Gynecol. Dec. 1993;82(6):984-6. Case-series. [pmid: 8233276].
4680 Viktrup L, Lose G. Lower urinary tract symptoms 5 years after the first delivery. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2000;11(6):336-40. Not eligible level of evidence. [pmid: 11147740].
4681 Viktrup L, Lose G. Do fertile women remember the onset of stress incontinence? Recall bias 5 years after 1st delivery. Acta Obstet Gynecol Scand. Oct. 2001;80(10):952-5. Not eligible outcomes. [pmid: 11580741].
4682 Viktrup L, Lose G. The risk of stress incontinence 5 years after first delivery. Am J Obstet Gynecol. Jul. 2001;185(1):82-7. Not eligible level of evidence. [pmid: 11483909].
4683 Vinker S, Kaplan B, Nakar S, et al. Urinary incontinence in women: prevalence, characteristics and effect on quality of life. A primary care clinic study. Isr Med Assoc J. Sep. 2001;3(9):663-6. Not eligible level of evidence. [pmid: 11574982].
4684 Vinsnes AG, Haltbakk J, Hunskaar S. A Norwegian version of the Incontinence Stress Questionnaire-Staff Reaction: translation and validation for cross-cultural use. J Nurs Meas. Summer. 2000;8(1):71-86. Not eligible exposure. [pmid: 11026167].
4685 Vinsnes AG, Hunskaar S. Distress associated with urinary incontinence, as measured by a visual analogue scale. Scand J Caring Sci. 1991;5(1):57-61. Not eligible outcomes. [pmid: 2011674].
4686 Vinson J, Proch J. Inhibition of moisture penetration to the skin by a novel incontinence barrier product. J Wound Ostomy Continence Nurs. Sep. 1998;25(5):256-60. Not eligible outcomes. [pmid: 9923260].
4687 Violi V, Boselli AS, De Bernardinis M, et al. Surgical results and functional outcome after total anorectal reconstruction by double graciloplasty supported by external-source electrostimulation and/or implantable pulse generators: an 8-year experience. Int J Colorectal Dis. May. 2004;19(3):219-27. Case-series. [pmid: 14586631].
4688 Violi V, Boselli AS, De Bernardinis M, et al. A patient-rated, surgeon-corrected scale for functional assessment after total anorectal reconstruction. An adaptation of the Working Party on Anal Sphincter Replacement scoring system. Int J Colorectal Dis. Sep. 2002;17(5):327-37. Not eligible outcomes. [pmid: 12172926].
4689 Violi V, Boselli AS, Sarli L, et al. Rectal cancer in anorectal malformation with rectovestibular fistula: sphincter-restoring surgery by anterior resection and dynamic vaginoanograciloplasty. Dis Colon Rectum. Jul. 2001;44(7):1043-8. Case Reports. [pmid: 11496087].
4690 Violi V, Roncoroni L, Boselli AS, et al. Continent perineal colostomy by electrostimulated graciloplasty in abdominoperineal resection. A preliminary report. Acta Biomed Ateneo Parmense. 1996;67(34):131-42. Case-series. [pmid: 10021696].
4691 Violi V, Roncoroni L, Boselli AS, et al. Total anorectal reconstruction by double graciloplasty: experience with delayed, selective use of implantable pulse generators. Int J Colorectal Dis. Aug. 1999;14(3):164-71. Not eligible target population. [pmid: 10460908].
4692 Virgili A, Corazza M, Califano A. Diaper dermatitis in an adult. A case of erythema papuloerosive of Sevestre and Jacquet. J Reprod Med. Nov. 1998;43(11):949-51. Case-reports. [pmid: 9839262].
4693 Vironen JH, Kairaluoma M, Aalto AM, et al. Impact of functional results on quality of life after rectal cancer surgery. Dis Colon Rectum. May. 2006;49(5):568-78. Case-series. [pmid: 16583289].
4694 Virtanen H, Hirvonen T, Makinen J, et al. Outcome of thirty patients who underwent repair of posthysterectomy prolapse of the vaginal vault with abdominal sacral colpopexy. J Am Coll Surg. Mar. 1994;178(3):283-7. Case-series. [pmid: 8149022].
4695 Virtanen H, Makinen J, Tenho T, et al. Effects of abdominal hysterectomy on urinary and sexual symptoms. Br J Urol. Dec. 1993;72(6):868-72. Case-series. [pmid: 8306148].
4696 Virtanen HS, Kiilholma P. Urogynecologic ultrasound is a useful aid in the assessment of female stress urinary incontinence—a prospective study with TVT procedure. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(4):218-22. discussion 23. Case-series. [pmid: 12189426].
4697 Virtanen HS, Makinen JI. Vesicocervical fistula—a rare cause of urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Oct. 1994;57(1):54-5. Case Reports. [pmid: 7821505].
4698 Visco AG, Weidner AC, Cundiff GW, et al. Observed patient compliance with a structured outpatient bladder retraining program. Am J Obstet Gynecol. Dec. 1999;181(6):1392-4. Not eligible outcomes. [pmid: 10601918].
4699 Viseshsindh W, Kochakarn W, Waikakul W, et al. A randomized controlled trial of pubovaginal sling versus vaginal wall sling for stress urinary incontinence. J Med Assoc Thai. Apr. 2003;86(4):308-15. Not available publication. [pmid: 12757074].
4700 Visser AJ, Heyns CF, Visser Jun AJ. Vesicosuspension for female stress incontinence and cystocele using pubic bone anchors. S Afr J Surg. Nov. 2001;39(4):129-32. Case-series. [pmid: 11820144].
4701 Voderholzer WA, Neuhaus DA, Klauser AG, et al. Paradoxical sphincter contraction is rarely indicative of anismus. Gut. Aug. 1997;41(2):258-62. Not eligible outcomes. [pmid: 9301508]. [pmcid: 1891465].
4702 Volk RJ, Cantor SB, Cass AR, et al. Preferences of husbands and wives for outcomes of prostate cancer screening and treatment. J Gen Intern Med. Apr. 2004;19(4):339-48. Not eligible target population. [pmid: 15061743]. [pmcid: 1492196].
4703 Volkan T, Ihsan TA, Yilmaz O, et al. Short term outcomes of high power (80 W) potassium-titanyl-phosphate laser vaporization of the prostate. Eur Urol. Oct. 2005;48(4):608-13. Q2. [pmid: 16135396].
4704 Volkmer BG, Kuefer R, Nesslauer T, et al. Colour Doppler ultrasound in vesicovaginal fistulas. Ultrasound Med Biol. Jun. 2000;26(5):771-5. Not eligible exposure. [pmid: 10942824].
4705 Volkmer BG, Nesslauer T, Rinnab L, et al. Surgical intervention for complications of tension-free vaginal tape procedure. J Urol. Feb. 2003;169(2):570-4. Case Reports. [pmid: 12544309].
4706 von Pechmann WS, Mutone M, Fyffe J, et al. Total colpocleisis with high levator plication for the treatment of advanced pelvic organ prolapse. Am J Obstet Gynecol. Jul. 2003;189(1):121-6. Case-series. [pmid: 12861149].
4707 von Theobald P, Barjot P, Levy G. Feasibility of and interest in laparoscopic assessment in recurrent urinary stress incontinence after Burch procedure performed by laparotomy. Surg Endosc. May. 1997;11(5):468-71. Not eligible exposure. [pmid: 9153177].
4708 von Theobald P, Guillaumin D, Levy G. Laparoscopic preperitoneal colposuspension for stress incontinence in women. Technique and results of 37 procedures. Surg Endosc. Nov. 1995;9(11):1189-92. Case-series. [pmid: 8553231].
4709 von Wendt L, Simila S, Niskanen P, et al. Development of bowel and bladder control in the mentally retarded. Dev Med Child Neurol. Jun. 1990;32(6):515-8. Not eligible target population. [pmid: 2365145].
4710 Voorham-van der Zalm PJ, Pelger RC, Stiggelbout AM, et al. Effects of magnetic stimulation in the treatment of pelvic floor dysfunction. BJU Int. May. 2006;97(5):1035-8. Case-series. [pmid: 16643487].
4711 Vorburger SA, Von Flue M, Harder F. Pelvic floor herniation after modified York-Mason approach to the rectum: report of a case. Dis Colon Rectum. Mar. 1998;41(3):389-90. Case Reports. [pmid: 9514438].
4712 Vordermark D, Flentje M, Sailer M, et al. Intracavitary afterloading boost in anal canal carcinoma. Results, function and quality of life. Strahlenther Onkol. May. 2001;177(5):252-8. Not eligible target population. [pmid: 11398611].
4713 Vordermark D, Schwab M, Flentje M, et al. Chronic fatigue after radiotherapy for carcinoma of the prostate: correlation with anorectal and genitourinary function. Radiother Oncol. Mar. 2002;62(3):293-7. Not eligible exposure. [pmid: 12175560].
4714 Vordermark D, Schwab M, Ness-Dourdoumas R, et al. Association of anorectal dose-volume histograms and impaired fecal continence after 3D conformal radiotherapy for carcinoma of the prostate. Radiother Oncol. Nov. 2003;69(2):209-14. Case-series. [pmid: 14643960].
4715 Vorobiev GI, Odaryuk TS, Tsarkov PV, et al. Resection of the rectum and total excision of the internal anal sphincter with smooth muscle plasty and colonic pouch for treatment of ultralow rectal carcinoma. Br J Surg. Nov. 2004;91(11):1506-12. Case-series. [pmid: 15455363].
4716 Votolato NA, Stern S, Caputo RM. Serotonergic antidepressants and urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2000;11(6):386-8. Case- Reports. [pmid: 11147747].
4717 Voyvodic F, Rieger NA, Skinner S, et al. Endosonographic imaging of anal sphincter injury: does the size of the tear correlate with the degree of dysfunction?. Dis Colon Rectum. Jun. 2003;46(6):735-41. Not eligible outcomes. [pmid: 12794574].
4718 Voyvodic F, Schloithe AC, Wattchow DA, et al. Delayed pudendal nerve conduction and endosonographic appearance of the anal sphincter complex. Dis Colon Rectum. Dec. 2000;43(12):1689-94. Case-series. [pmid: 11156452].
4719 Vujovic S, Zidverc J, Stojanovic M, et al. Drospirenone in the treatment of severe premenstrual cerebral edema in a woman with antiphospholipid syndrome, lateral sinus thrombosis, situs inversus and epileptic seizures. Gynecol Endocrinol. Nov. 2005;21(5):243-7. Case-reports. [pmid: 16373242].
4720 Waaldijk K. The immediate surgical management of fresh obstetric fistulas with catheter and/or early closure. Int J Gynaecol Obstet. Apr. 1994;45(1):11-6. Case-series. [pmid: 7913052].
4721 Waaldijk K. Surgical classification of obstetric fistulas. Int J Gynaecol Obstet. May. 1995;49(2):161-3. No associative hypothesis tested. [pmid: 7649321].
4722 Wade BE. Colostomy patients: psychological adjustment at 10 weeks and 1 year after surgery in districts which employed stoma-care nurses and districts which did not. J Adv Nurs. Nov. 1990;15(11):1297-304. Not eligible outcomes. [pmid: 2176666].
4723 Wadie BS, Shehab El-Dein AB, Mosbah A, et al. A 2-year follow-up after rotoresection of the prostate: a prospective study. BJU Int. Oct. 2005;96(6):828-30. Case-series. [pmid: 16153211].
4724 Waetjen LE, Subak LL, Shen H, et al. Stress urinary incontinence surgery in the United States. Obstet Gynecol. Apr. 2003;101(4):671-6. Not eligible level of evidence. [pmid: 12681869].
4725 Wagg A, Bayliss M, Ingham NJ, et al. Urodynamic variables cannot be used to classify the severity of detrusor instability. Br J Urol. Oct. 1998;82(4):499-502. Not eligible outcomes. [pmid: 9806177].
4726 Wagg A, Das Gupta R, Assassa P, et al. Secondary-care treatment patterns in the UK for women with urinary incontinence. BJU Int. Oct. 2005;96(6):839-42. Not eligible outcomes. [pmid: 16153213].
4727 Wagg A, Mian S, Lowe D, et al. National audit of continence care for older people: results of a pilot study*. J Eval Clin Pract. Dec. 2005;11(6):525-32. Not eligible outcomes. [pmid: 16364105].
4728 Wagner TH, Patrick DL, Bavendam TG, et al. Quality of life of persons with urinary incontinence: development of a new measure. Urology. Jan. 1996;47(1):67-71. discussion -2. Not eligible outcomes. [pmid: 8560665].
4729 Wagner VP, Osgood SB. Patient with a recessed, stenosed stoma located in an irregular, pendulous abdomen and the presence of pseudoverrucous lesions. J Wound Ostomy Continence Nurs. Sep. 1998;25(5):261-6. Case Reports. [pmid: 9923261].
4730 Wai CY, Atnip SD, Williams KN, et al. Urethral erosion of tension-free vaginal tape presenting as recurrent stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):353-5. Not eligible exposure. [pmid: 15580423].
4731 Wai CY, Margulis V, Baugh BR, et al. Multiple vesical calculi and complete vaginal vault prolapse. Am J Obstet Gynecol. Sep. 2003;189(3):884-5. Not eligible exposure. [pmid: 14526336].
4732 Wainstein MA, Klutke CG. Antegrade techniques of collagen injection for post-prostatectomy stress urinary incontinence: the Washington University experience. World J Urol. 1997;15(5):310-5. Case-series. [pmid: 9372583].
4733 Wainstein MA, Klutke CG. Periurethral pseudocyst following cystoscopic collagen injection. Urology. May. 1998;51(5):835-6. Case Reports. [pmid: 9610604].
4734 Wakavaiachi VM, Girao MJ, Sartori MG, et al. Changes in the lower urinary tract in continent women and in women with stress urinary incontinence, according to menopausal status. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(3):156-60. Case-series. [pmid: 11451002].
4735 Wakhlu A, Dalela D, Tandon RK, et al. The single ectopic ureter. Br J Urol. Aug. 1998;82(2):246-51. Not eligible target population. [pmid: 9722761].
4736 Wald A. Pathophysiology and management of fecal incontinence. Rev Gastroenterol Mex. Apr–Jun. 1994;59(2):139-46. Comment. [pmid: 7991967].
4737 Wald A. Fecal incontinence: three steps to successful management. Geriatrics 1997 Jul; 52(7):44–6, 9–52. Comment
4738 Waldron DJ, Horgan PG, Patel FR, et al. Multiple sclerosis: assessment of colonic and anorectal function in the presence of faecal incontinence. Int J Colorectal Dis. Dec. 1993;8(4):220-4. Case-series. [pmid: 8163898].
4739 Walker LJ, Evison JG, Garrett C. Recurrent pancreatitis: not just alcohol, gallstones and scorpion venom. J R Soc Med. Feb. 2004;97(2):82-3. Case Reports. [pmid: 14749407]. [pmcid: 1079298].
4740 Walker RD 3rd, Flack CE, Hawkins-Lee B, et al. Rectus fascial wrap: early results of a modification of the rectus fascial sling. J Urol. Aug. 1995;154(2 Pt 2):771-4. Case-series. [pmid: 7609176].
4741 Wall J, Colley T. A study to evaluate factors for inclusion in a new self-assessed risk indicator for persons who use a wheelchair for mobility. J Tissue Viability. Jan. 2005;15(1):9-16. Not eligible outcomes. [pmid: 15693583].
4742 Wall LL. Fitsari 'dan Duniya. An African (Hausa) praise song about vesicovaginal fistulas. Obstet Gynecol. Dec. 2002;100(6):1328-32. Comment. [pmid: 12468180].
4743 Wall LL, Addison WA. Prazosin-induced stress incontinence. Obstet Gynecol. Mar. 1990;75(3 Pt 2):558-60. Case report. [pmid: 2304736].
4744 Wall LL, Hewitt JK, Helms MJ. Are vaginal and rectal pressures equivalent approximations of one another for the purpose of performing subtracted cystometry?. Obstet Gynecol. Apr. 1995;85(4):488-93. Not eligible exposure. [pmid: 7898821].
4745 Wallace RA, Webb PM, Schluter PJ. Environmental, medical, behavioural and disability factors associated with Helicobacter pylori infection in adults with intellectual disability. J Intellect Disabil Res. Jan. 2002;46(Pt 1):51-60. Not eligible outcomes. [pmid: 11851856].
4746 Wallner K, Lee H, Wasserman S, et al. Low risk of urinary incontinence following prostate brachytherapy in patients with a prior transurethral prostate resection. Int J Radiat Oncol Biol Phys. Feb 1. 1997;37(3):565-9. Case-series. [pmid: 9112454].
4747 Wallwiener D, Grischke EM, Rimbach S, et al. Endoscopic retropubic colposuspension: “Retziusscopy” versus laparoscopy—a reasonable enlargement of the operative spectrum in the management of recurrent stress incontinence?. Endosc Surg Allied Technol. Apr–Jun. 1995;3(23):115-8. No associative hypothesis tested. [pmid: 7552124].
4748 Walsh IK, Williams SG, Mahendra V, et al. Artificial urinary sphincter implantation in the irradiated patient: safety, efficacy and satisfaction. BJU Int. Mar. 2002;89(4):364-8. Case-series. [pmid: 11872025].
4749 Walsh K, Generao SE, White MJ, et al. The influence of age on quality of life outcome in women following a tension-free vaginal tape procedure. J Urol. Mar. 2004;171(3):1185-8. Case-series. [pmid: 14767297].
4750 Walsh PC, Marschke P, Ricker D, et al. Patient-reported urinary continence and sexual function after anatomic radical prostatectomy. Urology. Jan. 2000;55(1):58-61. Case-series.
4751 Walsh PC, Marschke PL. Intussusception of the reconstructed bladder neck leads to earlier continence after radical prostatectomy. Urology. Jun. 2002;59(6):934-8. Case-series. [pmid: 12031385].
4752 Walsh PC, Partin AW. Treatment of early stage prostate cancer: radical prostatectomy. Important Adv Oncol 1994:211–23. Review
4753 Walter AJ, Morse AN, Hammer RA, et al. Laparoscopic versus open Burch retropubic urethropexy: comparison of morbidity and costs when performed with concurrent vaginal prolapse repairs. Am J Obstet Gynecol. Apr. 2002;186(4):723-8. Case-series. [pmid: 11967498].
4754 Walton JC, Miller JM. Evaluating physical and behavioral changes in older adults. Medsurg Nurs. Apr. 1998;7(2):85-90. Case Reports. [pmid: 9727122].
4755 Waltregny D, Reul O, Mathantu B, et al. Inside out transobturator vaginal tape for the treatment of female stress urinary incontinence: interim results of a prospective study after a 1-year minimum followup. J Urol. Jun. 2006;175(6):2191-5. Case-series. [pmid: 16697838].
4756 Wang AC. Burch colposuspension vs. Stamey bladder neck suspension. A comparison of complications with special emphasis on detrusor instability and voiding dysfunction. J Reprod Med. Jul. 1996;41(7):529-33. Not eligible target population. [pmid: 8829067].
4757 Wang AC. Bladder-sphincter biofeedback as treatment of detrusor instability in women who failed to respond to oxybutynin. Chang Gung Med J. Oct. 2000;23(10):590-9. Not eligible target population. [pmid: 11126150].
4758 Wang AC, Chen MC. Randomized comparison of local versus epidural anesthesia for tension-free vaginal tape operation. J Urol. Apr. 2001;165(4):1177-80. Not eligible outcomes. [pmid: 11257665].
4759 Wang AC, Lee LY, Lin CT, et al. A histologic and immunohistochemical analysis of defective vaginal healing after continence taping procedures: a prospective case-controlled pilot study. Am J Obstet Gynecol. Dec. 2004;191(6):1868-74. Not eligible exposure. [pmid: 15592267].
4760 Wang D, Yamana T, Iwadare J. Long-term results and quality-of-life outcomes in patients with transsphincteric fistulas after muscle-filling procedure. Dis Colon Rectum. Aug. 2002;45(8):1011-5. Not eligible target population. [pmid: 12195183].
4761 Wang KH, Wang KH, Neimark M, et al. Voiding dysfunction following TVT procedure. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2002;13(6):353-7. discussion 8. Case-series. [pmid: 12466905].
4762 Wang MY, Levi AD, Green BA. Intradural spinal arachnoid cysts in adults. Surg Neurol. Jul. 2003;60(1):49-55. discussion -6. Case-series. [pmid: 12865013].
4763 Wang PS, Levin R, Zhao SZ, et al. Urinary antispasmodic use and the risks of ventricular arrhythmia and sudden death in older patients. J Am Geriatr Soc. Jan. 2002;50(1):117-24. Not eligible outcomes. [pmid: 12028256].
4764 Wang R, Visootsak J, Danielpour M, et al. Midline defects in FG syndrome: does tethered spinal cord contribute to the phenotype?. J Pediatr. Apr. 2005;146(4):537-41. Not eligible target population. [pmid: 15812461].
4765 Wang WL, Li Z, Wang HZ, et al. Comprehensive assessment of long-term postoperative continence in pediatric imperforate anus. Clinical, manometric and contrast studies. Chin Med J (Engl). Nov. 1991;104(11):949-53. Not eligible target population. [pmid: 1800038].
4766 Wang Y, Lim LL, Heller RF, et al. A prediction model of 1-year mortality for acute ischemic stroke patients. Arch Phys Med Rehabil. Jul. 2003;84(7):1006-11. Not eligible outcomes. [pmid: 12881825].
4767 Wang Y, Lim LL, Levi C, et al. A prognostic index for 30-day mortality after stroke. J Clin Epidemiol. Aug. 2001;54(8):766-73. Not eligible level of evidence. [pmid: 11470384].
4768 Ward JF, Sebo TJ, Blute ML, et al. Salvage surgery for radiorecurrent prostate cancer: contemporary outcomes. J Urol. Apr. 2005;173(4):1156-60. Not eligible level of evidence. [pmid: 15758726].
4769 Warner JP, Harvey CA, Barnes TR. Clozapine and urinary incontinence. Int Clin Psychopharmacol. Sep. 1994;9(3):207-9. Case-series. [pmid: 7814831].
4770 Warren JW. Urine-collection devices for use in adults with urinary incontinence. J Am Geriatr Soc. Mar. 1990;38(3):364-7. Review. [pmid: 2313015].
4771 Warshaw E, Nix D, Kula J, et al. Clinical and cost effectiveness of a cleanser protectant lotion for treatment of perineal skin breakdown in low-risk patients with incontinence. Ostomy Wound Manage. Jun. 2002;48(6):44-51. Not eligible outcomes.
4772 Washington JL. Staple erosion into the bladder after mesh and staple laparoscopic colposuspension. A case report. J Reprod Med. Apr. 2002;47(4):325-6. Case Reports. [pmid: 12012886].
4773 Wasserberg N, Kaiser AM, Nunoo-Mensah JW, et al. Preservation of bowel and urinary continence in the management of locally recurrent rectal cancer. J Surg Oncol. Oct 1. 2005;92(1):76-81. Case-series. [pmid: 16180216].
4774 Wasserman GA. Correction of a vault suspension graft complication. J Am Assoc Gynecol Laparosc. May. 1995;2(3):359-61. Case Reports. [pmid: 9050586].
4775 Watanabe T, Rivas DA, Miettinen M, et al. Total incontinence secondary to sphincter destruction after prostate cryotherapy for recurrent prostatic carcinoma. Int J Urol. Jul. 1996;3(4):324-5. Case-reports. [pmid: 8844295].
4776 Watanabe T, Yokoyama T, Sasaki K, et al. Intravesical resiniferatoxin for patients with neurogenic detrusor overactivity. Int J Urol. Apr. 2004;11(4):200-5. Not eligible target population. [pmid: 15028097].
4777 Watson AJ, Currie I, Curran S, et al. A prospective study examining the association between the symptoms of anxiety and depression and severity of urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Jan. 2000;88(1):7-9. Not eligible outcomes. [pmid: 10659910].
4778 Watson AJ, Currie I, Jarvis GJ. A prospective placebo controlled double blind randomised study to investigate the use of indoramin to prevent post-operative voiding disorders after surgical treatment for genuine stress incontinence. Br J Obstet Gynaecol. Mar. 1999;106(3):270-2. Not eligible exposure. [pmid: 10426648].
4779 Watson R. Incontinence in perspective. Nursing (Lond). Jul 25–Aug 21. 1991;4(39):7-10. Comment. [pmid: 1881649].
4780 Watson R, Kuhn M. The influence of component parts on the performance of urinary sheath systems. J Adv Nurs. Apr. 1990;15(4):417-22. Not eligible exposure. [pmid: 2341686].
4781 Weatherall M, Arnold T. Nocturia in adults: draft New Zealand guidelines for its assessment and management in primary care. N Z Med J. 2006;119(1234):U1976. Guideline. [pmid: 16718287].
4782 Weatherall M, Slow T, Wiltshire K. Risk factors for entry into residential care after a support-needs assessment. N Z Med J. Sep 24. 2004;117(1202):U1075. Not eligible level of evidence. [pmid: 15477909].
4783 Weaver A, Dobson P, Swithinbank L. Addressing the needs of teenagers with continence problems. Nurs Times. May 18. 2004;100(20):61-3. Review.
4784 Webb HW, Barraza MA, Crump JM. Laparoscopic appendicostomy for management of fecal incontinence. J Pediatr Surg. Mar. 1997;32(3):457-8. Not eligible target population. [pmid: 9094017].
4785 Webb J. Continence: help for the elderly confused. Nurs Times. Apr 18–24. 1990;86(16):64-8. Comment. [pmid: 2330323].
4786 Webb ML. Urinary incontinence in younger women. Nurse Pract Forum. Sep. 1994;5(3):164-9. Not eligible outcomes. [pmid: 7950496].
4787 Webb S, Patterson V, Hutchinson M. Two families with autosomal recessive spastic paraplegia, pigmented maculopathy, and dementia. J Neurol Neurosurg Psychiatry. Nov. 1997;63(5):628-32. Not eligible exposure. [pmid: 9408105]. [pmcid: 2169835].
4788 Webb V, Simpson R. Older man's burden. Nurs Times. Jan 29–Feb 4. 1997;93(5):77-80. No associative hypothesis tested. [pmid: 9070007].
4789 Weber AM, Taylor RJ, Wei JT, et al. The cost-effectiveness of preoperative testing (basic office assessment vs. urodynamics) for stress urinary incontinence in women. BJU Int. Mar. 2002;89(4):356-63. Not eligible outcomes. [pmid: 11872024].
4790 Weber AM, Walters MD, Piedmonte MR. Sexual function and vaginal anatomy in women before and after surgery for pelvic organ prolapse and urinary incontinence. Am J Obstet Gynecol. Jun. 2000;182(6):1610-5. Not eligible outcomes. [pmid: 10871485].
4791 Weber AM, Walters MD, Schover LR, et al. Functional outcomes and satisfaction after abdominal hysterectomy. Am J Obstet Gynecol. Sep. 1999;181(3):530-5. Case-series. [pmid: 10486459].
4792 Weber AM, Walters MD, Schover LR, et al. Sexual function in women with uterovaginal prolapse and urinary incontinence. Obstet Gynecol. Apr. 1995;85(4):483-7. Not eligible outcomes. [pmid: 7898820].
4793 Weber BA, Roberts BL, Resnick M, et al. The effect of dyadic intervention on self-efficacy, social support, and depression for men with prostate cancer. Psychooncology. Jan. 2004;13(1):47-60. Not eligible outcomes. [pmid: 14745745].
4794 Webster JJ, Williams G. Adhesions of the labia minora. Br J Urol. Jul. 1996;78(1):146-7. Case Reports. [pmid: 8795428].
4795 Webster TM, Gerridzen RG. Urethral erosion following autologous rectus fascial pubovaginal sling. Can J Urol. Dec. 2003;10(6):2068-9. Case Reports. [pmid: 14704112].
4796 Weckermann D, Wawroschek F, Schipp J, et al. Metabolic changes and urodynamic findings after continent urinary diversion. Int Urol Nephrol. 1999;31(5):665-74. Case-series. [pmid: 10755358].
4797 Wedderburn A, Lee RS, Denny A, et al. Synchronous bladder reconstruction and antegrade continence enema. J Urol. Jun. 2001;165(6 Pt 2):2392-3. Not eligible target population. [pmid: 11371984].
4798 Weese DL, Roskamp DA, Leach GE, et al. Intravesical oxybutynin chloride: experience with 42 patients. Urology. Jun. 1993;41(6):527-30. Case-series. [pmid: 8516987].
4799 Wehle MJ, Lisson SW, Buskirk SJ, et al. Prediction of genitourinary tract morbidity after brachytherapy for prostate adenocarcinoma. Mayo Clin Proc. Mar. 2004;79(3):314-7. Case-series. [pmid: 15008604].
4800 Wei JT, Dunn RL, Marcovich R, et al. Prospective assessment of patient reported urinary continence after radical prostatectomy. J Urol. Sep. 2000;164(3 Pt 1):744-8. Case-series. [pmid: 10953138].
4801 Wei JT, Montie JE. Comparison of patients' and physicians' rating of urinary incontinence following radical prostatectomy. Semin Urol Oncol. Feb. 2000;18(1):76-80. Not eligible outcomes. [pmid: 10719937].
4802 Wei TS, Su TH. Tension-free vaginal tape failure caused by sling displacement and successfully retreated using Burch colposuspension. Acta Obstet Gynecol Scand. Apr. 2003;82(4):385-6. Case-reports. [pmid: 12716325].
4803 Weidner AC, Barber MD, Visco AG, et al. Pelvic muscle electromyography of levator ani and external anal sphincter in nulliparous women and women with pelvic floor dysfunction. Am J Obstet Gynecol. Dec. 2000;183(6):1390-9. discussion 9–401. Not eligible outcomes. [pmid: 11120502].
4804 Weigel R, Senn P, Weis J, et al. Severe complications after intrathecal methotrexate (MTX) for treatment of primary central nervous system lymphoma (PCNSL). Clin Neurol Neurosurg. Mar. 2004;106(2):82-7. Case Reports. [pmid: 15003295].
4805 Weil EH, Eerdmans PH, Dijkman GA, et al. Randomized double-blind placebo-controlled multicenter evaluation of efficacy and dose finding of midodrine hydrochloride in women with mild to moderate stress urinary incontinence: a phase II study. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(3):145-50. Not eligible exposure. [pmid: 9745973].
4806 Weil EH, van Waalwijk van Doorn ES, Heesakkers JP, et al. Transvaginal ultrasonography: a study with healthy volunteers and women with genuine stress incontinence. Eur Urol. 1993;24(2):226-30. Not eligible outcomes. [pmid: 8375444].
4807 Wein AJ. Overactive bladder: defining the disease. Am J Manag Care. Jul. 2000;6(11 Suppl):S559-64. discussion S607–19. Comment. [pmid: 11183898].
4808 Wein AJ. Impact of urinary incontinence after stroke: results from a prospective population-based stroke register. J Urol. Jun. 2005;173(6):2057. Not eligible outcomes. [pmid: 15879829].
4809 Wein AJ. Transvaginal surgery in the octogenarian using cadaveric fascia for pelvic prolapse and stress incontinence: minimal one-year results compared to younger patients. J Urol. Sep. 2005;174(3):1009. Case-series.
4810 Wein AJ. Antidiuresis: a new concept in managing female daytime urinary incontinence. J Urol. Jun. 2005;173(6):2054-5. Comment.
4811 Wein AJ, Khullar V, Wang JT, et al. Achieving continence with antimuscarinic therapy for overactive bladder: effects of baseline incontinence severity and bladder diary duration. BJU Int. Feb. 2007;99(2):360-3. secondary data analysis. [pmid: 17155987].
4812 Weinberger MW, Goodman BM, Carnes M. Long-term efficacy of nonsurgical urinary incontinence treatment in elderly women. J Gerontol A Biol Sci Med Sci. Mar. 1999;54(3):M117-21. Case-series. [pmid: 10191838].
4813 Weinberger MW, Julian TM. Voiding dysfunction and incontinence caused by uterine retroversion. A case report. J Reprod Med. May. 1995;40(5):387-90. Case Reports. [pmid: 7608882].
4814 Weinberger MW, Ostergard DR. Long-term clinical and urodynamic evaluation of the polytetrafluoroethylene suburethral sling for treatment of genuine stress incontinence. Obstet Gynecol. Jul. 1995;86(1):92-6. Case-series. [pmid: 7784030].
4815 Weinberger MW, Ostergard DR. Postoperative catheterization, urinary retention, and permanent voiding dysfunction after polytetrafluroethylene suburethral sling placement. Obstet Gynecol. Jan. 1996;87(1):50-4. Case-series. [pmid: 8532265].
4816 Weinstein DL, Cohen JS, Liu C, et al. Duloxetine in the treatment of women with stress urinary incontinence: results from DESIRE (Duloxetine Efficacy and Safety for Incontinence in Racial and Ethnic populations). Curr Med Res Opin. Nov. 2006;22(11):2121-9. Not eligible exposure. [pmid: 17076972].
4817 Weir NU, Counsell CE, McDowall M, et al. Reliability of the variables in a new set of models that predict outcome after stroke. J Neurol Neurosurg Psychiatry. Apr. 2003;74(4):447-51. Not eligible outcomes. [pmid: 12640061]. [pmcid: 1738385].
4818 Weiss JP, Blaivas JG, Stember DS, et al. Nocturia in adults: etiology and classification. Neurourol Urodyn. 1998;17(5):467-72. Not eligible outcomes. [pmid: 9776009].
4819 Weiss RE, Garden RJ, Cohen EL, et al. Covered exstrophy with sequestered colonic remnant. J Urol. Jul. 1993;150(1):185-7. Case report. [pmid: 8510249].
4820 Wells JA, Ouslander JG, Meadows E, et al. Urinary incontinence in a geriatric patient with a complex neurologic history. J Wound Ostomy Continence Nurs. Sep. 1999;26(5):270-4. discussion 4–5. Case-reports. [pmid: 10795211].
4821 Wells T. Conquering incontinence. Geriatr Nurs. May–Jun. 1990;11(3):133-5. Comment. [pmid: 2163946].
4822 Welz-Barth A, Fusgen I, Melchior HJ. 1999 rerun of the 1996 German Urinary Incontinence Survey: will doctors ever ask?. World J Urol. Dec. 2000;18(6):436-8. Not eligible outcomes. [pmid: 11204265].
4823 Wenning GK, Scherfler C, Granata R, et al. Time course of symptomatic orthostatic hypotension and urinary incontinence in patients with postmortem confirmed parkinsonian syndromes: a clinicopathological study. J Neurol Neurosurg Psychiatry. Nov. 1999;67(5):620-3. Case-series. [pmid: 10519868]. [pmcid: 1736638].
4824 Werbrouck P, Baert L, Binard JE, et al. Balloon dilatation of the external urethral sphincter: a case study. J Am Paraplegia Soc. Apr. 1990;13(2):13-4. Case Reports.
4825 Werner M, Najjari L, Schuessler B. Transurethral resection of tension-free vaginal tape penetrating the urethra. Obstet Gynecol. Nov. 2003;102(5 Pt 1):1034-6. Case-reports. [pmid: 14672482].
4826 Werner M, Schmid DM, Schussler B. Efficacy of botulinum-A toxin in the treatment of detrusor overactivity incontinence: a prospective nonrandomized study. Am J Obstet Gynecol. May. 2005;192(5):1735-40. Not eligible target population. [pmid: 15902187].
4827 West RL, Dwarkasing S, Briel JW, et al. Can three-dimensional endoanal ultrasonography detect external anal sphincter atrophy? A comparison with endoanal magnetic resonance imaging. Int J Colorectal Dis. Jul. 2005;20(4):328-33. Not eligible target population. [pmid: 15666154].
4828 West RL, Felt-Bersma RJ, Hansen BE, et al. Volume measurements of the anal sphincter complex in healthy controls and fecal-incontinent patients with a three-dimensional reconstruction of endoanal ultrasonography images. Dis Colon Rectum. Mar. 2005;48(3):540-8. Not eligible outcomes. [pmid: 15747081].
4829 Westerterp M, Volkers NA, Poolman RW, et al. Anal fistulotomy between Skylla and Charybdis. Colorectal Dis. Nov. 2003;5(6):549-51. Case-series. [pmid: 14617238].
4830 Westney OL, Bevan-Thomas R, Palmer JL, et al. Transurethral collagen injections for male intrinsic sphincter deficiency: the University of Texas-Houston experience. J Urol. Sep. 2005;174(3):994-7. Case-series. [pmid: 16094021].
4831 Westney OL, Lee JT, McGuire EJ, et al. Long-term results of Ingelman-Sundberg denervation procedure for urge incontinence refractory to medical therapy. J Urol. Sep. 2002;168(3):1044-7. Case-series. [pmid: 12187219].
4832 Westney OL, Scott S, Wood C, et al. Suburethral sling at the time of radical prostatectomy in patients at high risk of postoperative incontinence. BJU Int. Aug. 2006;98(2):308-13. Case-series. [pmid: 16879670].
4833 Weston PM, Morgan JD, Hussain J, et al. Artificial urinary sphincters around intestinal segments—are they safe?. Br J Urol. Feb. 1991;67(2):150-4. Case-series. [pmid: 2004225].
4834 Wexner SD, Jorge JM. Colorectal physiological tests: use or abuse of technology?. Eur J Surg. Mar. 1994;160(3):167-74. Not eligible outcomes. [pmid: 8003569].
4835 Wexner SD, Reissman P, Pfeifer J, et al. Laparoscopic colorectal surgery: analysis of 140 cases. Surg Endosc. Feb. 1996;10(2):133-6. Not eligible level of evidence. [pmid: 8932614].
4836 Wheeler JS Jr, Walter JS, Sibley P. Management of incontinent SCI patients with penile stimulation: preliminary results. J Am Paraplegia Soc. Apr. 1994;17(2):55-9. Case-series. [pmid: 8064287].
4837 Wheeler TL 2nd, Richter HE, Duke AG, et al. Outcomes with porcine graft placement in the anterior vaginal compartment in patients who undergo high vaginal uterosacral suspension and cystocele repair. Am J Obstet Gynecol. May. 2006;194(5):1486-91. Case-series. [pmid: 16647932].
4838 Whishaw DM, Fonda D. Is there a role for drug therapy in the treatment of urinary incontinence in the elderly?. Med J Aust. Apr 4. 1994;160(7):430-5. Comment. [pmid: 8007867].
4839 White H, Holland D. Looking good and feeling good: clothes to help promote continence. Nurs Times. May 17–23. 2001;97(20):60-1. Comment. [pmid: 11962051].
4840 White M. Spina bifida: the personal and financial cost of incontinence. Br J Nurs 1993 Dec 9–1994 Jan 12; 2(22):1123–4, 6–30; discussion 30–2. Case Reports
4841 Whitebird RR, Bliss DZ, Hase KA, et al. Community-based recruitment and enrollment for a clinical trial on the sensitive issue of fecal incontinence: the Fiber study. Res Nurs Health. Jun. 2006;29(3):233-43. No associative hypothesis tested. [pmid: 16676338].
4842 Whiteside JL, Hijaz A, Imrey PB, et al. Reliability and agreement of urodynamics interpretations in a female pelvic medicine center. Obstet Gynecol. Aug. 2006;108(2):315-23. Not eligible outcomes. [pmid: 16880301].
4843 Whiteside JL, Weber AM, Meyn LA, et al. Risk factors for prolapse recurrence after vaginal repair. Am J Obstet Gynecol. Nov. 2004;191(5):1533-8. Not eligible outcomes. [pmid: 15547521].
4844 Whittingham K, May S. Cleansing regimens for continence care. Prof Nurse. Dec. 1998;14(3):167-72. Not eligible outcomes. [pmid: 10095686].
4845 Widgerow AD. Abdominoplasty following colostomy. Ann Plast Surg. Nov. 1992;29(5):454-6. Case Reports. [pmid: 1444137].
4846 Wielink G, Essink-Bot ML, van Kerrebroeck PE, et al. Sacral rhizotomies and electrical bladder stimulation in spinal cord injury. 2. Cost-effectiveness and quality of life analysis. Dutch Study Group on Sacral Anterior Root Stimulation. Eur Urol. 1997;31(4):441-6. Case-series. [pmid: 9187905].
4847 Wiesel PH, Norton C, Roy AJ, et al. Gut focused behavioural treatment (biofeedback) for constipation and faecal incontinence in multiple sclerosis. J Neurol Neurosurg Psychiatry. Aug. 2000;69(2):240-3. Not eligible target population. [pmid: 10896701]. [pmcid: 1737071].
4848 Wietek BM, Hinninghofen H, Jehle EC, et al. Asymmetric sphincter innervation is associated with fecal incontinence after anal sphincter trauma during childbirth. Neurourol Urodyn. 2007;26(1):134-9. Not eligible outcomes. [pmid: 16941639].
4849 Wijma J, Tinga DJ, Visser GH. Perineal ultrasonography in women with stress incontinence and controls: the role of the pelvic floor muscles. Gynecol Obstet Invest. 1991;32(3):176-9. Not eligible outcomes. [pmid: 1756999].
4850 Wijma J, Weis AE, de Wolf BT, et al. Anatomical and functional changes in the lower urinary tract during pregnancy. Bjog. Jul. 2001;108(7):726-32. Not eligible exposure. [pmid: 11467699].
4851 Wilbur J, Miller AM, Montgomery A, et al. Sociodemographic characteristics, biological factors, and symptom reporting in midlife women. Menopause. Spring. 1998;5(1):43-51. Not eligible level of evidence. [pmid: 9689194].
4852 Wilking SV, Sinclair AJ, Dickinson EJ. Exploring joint research initiatives: opportunities for collaboration between the US and the UK. J Am Geriatr Soc. Mar. 1998;46(3):291-2. Comment. [pmid: 9514374].
4853 Wilkins K. Medications and fall-related fractures in the elderly. Health Rep 1999 Summer; 11(1):45–53(Eng); 49–58(Fre). Not eligible outcomes
4854 Wilkinson K. Pakistani women's perceptions and experiences of incontinence. Nurs Stand. Oct 17–23. 2001;16(5):33-9. Case-series. [pmid: 11977796].
4855 Willams NS, Hallan RI, Koeze TH, et al. Construction of a neoanal sphincter by transposition of the gracilis muscle and prolonged neuromuscular stimulation for the treatment of faecal incontinence. Ann R Coll Surg Engl. Mar. 1990;72(2):108-13. Case-series. [pmid: 2334092]. [pmcid: 2499126].
4856 Wille S, Mills RD, Studer UE. Absence of urethral post-void milking: an additional cause for incontinence after radical prostatectomy?. Eur Urol. Jun. 2000;37(6):665-9. Case-series. [pmid: 10828665].
4857 Wille S, Varga Z, von Knobloch R, et al. Intussusception of bladder neck improves early continence after radical prostatectomy: results of a prospective trial. Urology. Mar. 2005;65(3):524-7. Case-series. [pmid: 15780369].
4858 Willener R, Hantikainen V. Individual quality of life following radical prostatectomy in men with prostate cancer. Urol Nurs 2005 Apr; 25(2):88–90, 5–100. Not eligible outcomes
4859 Williams AB, Malouf AJ, Bartram CI, et al. Assessment of external anal sphincter morphology in idiopathic fecal incontinence with endocoil magnetic resonance imaging. Dig Dis Sci. Jul. 2001;46(7):1466-71. Not eligible outcomes. [pmid: 11478498].
4860 Williams AB, Spencer JA, Bartram CI. Assessment of third degree tears using three-dimensional anal endosonography with combined anal manometry: a novel technique. Bjog. Jul. 2002;109(7):833-5. Not eligible outcomes. [pmid: 12135222].
4861 Williams D, Moran S. Use of urinary sheaths in male incontinence. Nurs Times 2006 Nov 21–27; 102(47):42, 4–5. Comment
4862 Williams ER, Malone PS. The social implications of lower urinary tract reconstruction performed during childhood. Br J Urol. Aug. 1995;76(2):226-30. Not eligible exposure. [pmid: 7663916].
4863 Williams JG, MacLeod CA, Rothenberger DA, et al. Seton treatment of high anal fistulae. Br J Surg. Oct. 1991;78(10):1159-61. Case-series. [pmid: 1958973].
4864 Williams JG, Rothenberger DA, Madoff RD, et al. Treatment of rectal prolapse in the elderly by perineal rectosigmoidectomy. Dis Colon Rectum. Sep. 1992;35(9):830-4. Case-series. [pmid: 1511640].
4865 Williams JG, Wong WD, Jensen L, et al. Incontinence and rectal prolapse: a prospective manometric study. Dis Colon Rectum. Mar. 1991;34(3):209-16. Case-series. [pmid: 1999126].
4866 Williams K. Good practice guidance for continence services. Nurs Times. Aug 3. 2000;96(31 Suppl):23-4. Guidance. [pmid: 11963700].
4867 Williams KS, Crichton NJ, Roe B. Disseminating research evidence. A controlled trial in continence care. J Adv Nurs. Apr. 1997;25(4):691-8. Not eligible outcomes. [pmid: 9104664].
4868 Williams ME, Richman J, Scatliff J. A 67-year-old woman with a progressive gait disturbance. J Am Geriatr Soc. Jul. 1996;44(7):843-6. Case report. [pmid: 8675937].
4869 Williams N, Barlow J, Hobson A, et al. Manometric asymmetry in the anal canal in controls and patients with fecal incontinence. Dis Colon Rectum. Dec. 1995;38(12):1275-80. Question 4. [pmid: 7497839].
4870 Williams NS, Ogunbiyi OA, Scott SM, et al. Rectal augmentation and stimulated gracilis anal neosphincter: a new approach in the management of fecal urgency and incontinence. Dis Colon Rectum. Feb. 2001;44(2):192-8. Case- Reports. [pmid: 11227935].
4871 Williams NS, Patel J, George BD, et al. Development of an electrically stimulated neoanal sphincter. Lancet. Nov 9. 1991;338(8776):1166-9. Case-series. [pmid: 1682591].
4872 Williams R. Promoting continence following head injury. Br J Nurs 1992 Jun 25–Jul 8; 1(5):236–7, 9–40. Case Reports
4873 Williams T. Nursing initiative pinpointed problem. N Z Nurs J. Feb. 1993;86(1):14. [pmid: 8455879].
4874 Williamson ME, Lewis WG, Miller AS, et al. Clinical and physiological evaluation of anorectal eversion during restorative proctocolectomy. Br J Surg. Oct. 1995;82(10):1391-4. Case-series. [pmid: 7489175].
4875 Willis J. Continence: a case for home delivery services. Nurs Times. Nov 25–Dec 1. 1998;94(47):64-6. Case Reports. [pmid: 9934156].
4876 Willis S, Faridi A, Schelzig S, et al. Childbirth and incontinence: a prospective study on anal sphincter morphology and function before and early after vaginal delivery. Langenbecks Arch Surg. Jun. 2002;387(2):101-7. Case-series. [pmid: 12111263].
4877 Wilmshurst JM, Kelly R, Borzyskowski M. Presentation and outcome of sacral agenesis: 20 years' experience. Dev Med Child Neurol. Dec. 1999;41(12):806-12. Not eligible target population. [pmid: 10619278].
4878 Wilson L, Brown JS, Shin GP, et al. Annual direct cost of urinary incontinence. Obstet Gynecol. Sep. 2001;98(3):398-406. Secondary data analysis. [pmid: 11530119].
4879 Wilson M. Male external collecting devices: management of a difficult case. Urol Nurs. Dec. 1993;13(4):130-1. Case Reports. [pmid: 8291001].
4880 Wilson M. The impact of faecal incontinence on the quality of life. Br J Nurs. Feb 22–Mar 7. 2007;16(4):204-7. No associative hypothesis tested. [pmid: 17363849].
4881 Wilson S, Quek ML, Ginsberg DA. Transurethral injection of bulking agents for stress urinary incontinence following orthotopic neobladder reconstruction in women. J Urol. Jul. 2004;172(1):244-6. Case-series. [pmid: 15201784].
4882 Wilson TS, Zimmern PE. Tailor-made incontinence care. Match type of incontinence to resident assessment for optimal treatment. Part 2. Contemp Longterm Care. Sep. 2002;25(9):18-20. Comment.
4883 Wilson TS, Zimmern PE. Urinary incontinence in elderly women. Contemp Longterm Care. Aug. 2002;25(8):18-20. Review.
4884 Winde G, Reers B, Nottberg H, et al. Clinical and functional results of abdominal rectopexy with absorbable mesh-graft for treatment of complete rectal prolapse. Eur J Surg. May. 1993;159(5):301-5. No associative hypothesis tested. [pmid: 8103365].
4885 Winters JC, Appell RA, Rackley RR. Urodynamic findings in postprostatectomy incontinence. Neurourol Urodyn. 1998;17(5):493-8. Case-series. [pmid: 9776012].
4886 Wise TN. Psychosocial side effects of sildenafil therapy for erectile dysfunction. J Sex Marital Ther. Apr–Jun. 1999;25(2):145-50. Case Reports. [pmid: 10327384].
4887 Wiseman PA, Malone-Lee J, Rai GS. Terodiline with bladder retraining for treating detrusor instability in elderly people. BMJ. Apr 27. 1991;302(6783):994-6. Not eligible exposure. [pmid: 2039897]. [pmcid: 1669297].
4888 Wollin J, Bennie M, Leech C, et al. Multiple sclerosis and continence issues: an exploratory study. Br J Nurs 2005 Apr 28–May 11; 14(8):439–40, 42, 44–6. Case-series
4889 Wolters M, Methfessel HD, Goepel C, et al. Computer-assisted virtual urethral pressure profile in the assessment of female genuine stress incontinence. Obstet Gynecol. Jan. 2002;99(1):69-74. Not eligible level of evidence. [pmid: 11777513].
4890 Wong EY. Uterine didelphys and occult spinal dysraphism: an unusual case. Dev Med Child Neurol. Feb. 1998;40(2):124-5. Case report. [pmid: 9489502].
4891 Wong L. Incontinence has different meanings for different people. Aust J Adv Nurs. Spring. 1995;13(1):6-15. Not eligible outcomes. [pmid: 7546464].
4892 Wong MY, Harmanli OH, Agar M, et al. Collagen content of nonsupport tissue in pelvic organ prolapse and stress urinary incontinence. Am J Obstet Gynecol. Dec. 2003;189(6):1597-9. discussion 9–600. Not eligible outcomes. [pmid: 14710077].
4893 Wong WD, Jensen LL, Bartolo DC, et al. Artificial anal sphincter. Dis Colon Rectum. Dec. 1996;39(12):1345-51. Case-series. [pmid: 8969658].
4894 Wong WS, Chinn DO, Chinn M, et al. Cryosurgery as a treatment for prostate carcinoma: results and complications. Cancer. Mar 1. 1997;79(5):963-74. Case-series. [pmid: 9041159].
4895 Woo HH, Rosario DJ, Chapple CR. Stone formation on permanent suture material used previously in colposuspension. Br J Urol. Jul. 1995;76(1):139-40. Case Reports. [pmid: 7648051].
4896 Woo J, Ho SC, Lau J, et al. The prevalence of depressive symptoms and predisposing factors in an elderly Chinese population. Acta Psychiatr Scand. Jan. 1994;89(1):8-13. Not eligible outcomes. [pmid: 8140912].
4897 Wood DN, Allen SE, Hussain M, et al. Stomal complications of ileal conduits are significantly higher when formed in women with intractable urinary incontinence. J Urol. Dec. 2004;172(6 Pt 1):2300-3. Not eligible target population. [pmid: 15538253].
4898 Woodhouse CR. Reconstruction of the lower urinary tract for neurogenic bladder: lessons from the adolescent age group. Br J Urol. Jun. 1992;69(6):589-93. Not eligible target population. [pmid: 1638344].
4899 Woodhouse CR, Christofides M. Modified ureterosigmoidostomy (Mainz II)—technique and early results. Br J Urol. Feb. 1998;81(2):247-52. Case-series. [pmid: 9488067].
4900 Woodhouse CR, Gordon EM. The Mitrofanoff principle for urethral failure. Br J Urol. Jan. 1994;73(1):55-60. Not eligible target population. [pmid: 8298900].
4901 Woodhouse CR, MacNeily AE. The Mitrofanoff principle: expanding upon a versatile technique. Br J Urol. Oct. 1994;74(4):447-53. Case-series. [pmid: 7820422].
4902 Woodman PJ, Davis GD. The relationship of the in-situ advancing vaginal wall sling to vaginal epithelial inclusion cyst. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(2):124-6. Case Reports. [pmid: 10805271].
4903 Woodman PJ, Misko CA, Fischer JR. The use of short-form quality of life questionnaires to measure the impact of imipramine on women with urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(5):312-5. discussion 5–6. Not eligible target population. [pmid: 11715997].
4904 Woods D, Dobranowski J, Orovan WL, et al. The Koch pouch: radiographic evaluation of the orthotopic and cutaneous forms. Can Assoc Radiol J. Apr. 1991;42(2):119-26. Case-series. [pmid: 2039953].
4905 Woods R, Voyvodic F, Schloithe AC, et al. Anal sphincter tears in patients with rectal prolapse and faecal incontinence. Colorectal Dis. Nov. 2003;5(6):544-8. Case-series. [pmid: 14617237].
4906 Wozniak-Petrofsky J. Urinary incontinence in the elderly: not a normal part of aging. Urol Nurs. Mar. 1993;13(1):12-6. Comment. [pmid: 8451657].
4907 Wraige E, Borzyskowski M. Investigation of daytime wetting: when is spinal cord imaging indicated?. Arch Dis Child. Aug. 2002;87(2):151-5. Not eligible target population. [pmid: 12138070]. [pmcid: 1719171].
4908 Wren FJ, Reese CT, Decter RM. Durability of the Malone antegrade continence enema in pregnancy. Urology. Mar. 2003;61(3):644. Case-reports. [pmid: 12639672].
4909 Wright EJ, Iselin CE, Carr LK, et al. Pubovaginal sling using cadaveric allograft fascia for the treatment of intrinsic sphincter deficiency. J Urol. Sep. 1998;160(3 Pt 1):759-62. Case-series. [pmid: 9720541].
4910 Wright L. The efficacy of bowel management in the adult with spina bifida. Eur J Pediatr Surg. Dec. 2002;12(Suppl 1):S41-3. Comment. [pmid: 12585258].
4911 Wszolek ZK, Pfeiffer RF, Bhatt MH, et al. Rapidly progressive autosomal dominant parkinsonism and dementia with pallido-ponto-nigral degeneration. Ann Neurol. Sep. 1992;32(3):312-20. Case Reports. [pmid: 1416801].
4912 Wu EQ, Birnbaum H, Marynchenko M, et al. Employees with overactive bladder: work loss burden. J Occup Environ Med. May. 2005;47(5):439-46. Not eligible outcomes. [pmid: 15891521].
4913 Wu J, Baguley IJ. Urinary retention in a general rehabilitation unit: prevalence, clinical outcome, and the role of screening. Arch Phys Med Rehabil. Sep. 2005;86(9):1772-7. Not eligible outcomes. [pmid: 16181941].
4914 Wydra D, Emerich J, Ciach K, et al. The role of pelvic exenteration for treatment of pelvic malignancy—a nine-year experience. Eur J Gynaecol Oncol. 2005;26(4):418-22. Case-series. [pmid: 16122192].
4915 Wydra D, Emerich J, Sawicki S, et al. Major complications following exenteration in cases of pelvic malignancy: a 10-year experience. World J Gastroenterol. Feb 21. 2006;12(7):1115-9. Case-series. [pmid: 16534855].
4916 Wyman JF. Managing urinary incontinence with bladder training: a case study. J ET Nurs. May–Jun. 1993;20(3):121-6. Case Reports. [pmid: 8394146].
4917 Wyman JF, Bliss DZ, Dougherty MC, et al. Shaping future directions for incontinence research in aging adults: executive summary. Nurs Res. Nov–Dec. 2004;53(6 Suppl):S1-10. Comment. [pmid: 15586141].
4918 Wyman JF, Elswick RK Jr, Ory MG, et al. Influence of functional, urological, and environmental characteristics on urinary incontinence in community-dwelling older women. Nurs Res. Sep–Oct. 1993;42(5):270-5. Not eligible target population. [pmid: 8415039].
4919 Wyndaele JJ, Maes D. Clean intermittent self-catheterization: a 12-year followup. J Urol. May. 1990;143(5):906-8. Case-series. [pmid: 2329604].
4920 Wynne JM, Myles JL, Jones I, et al. Disturbed anal sphincter function following vaginal delivery. Gut. Jul. 1996;39(1):120-4. Not eligible level of evidence. [pmid: 8881822]. [pmcid: 1383244].
4921 Xiao YH, Liu GL. Manometric asymmetry of the anal sphincter: anatomic evidence and clinical application. Chin Med J (Engl). Feb 5. 2005;118(3):210-4. Not eligible target population. [pmid: 15740649].
4922 Xu Z, Fu Q. Bulbocavernosus muscle flap in the repair of complicated vesicovaginal fistula. Int J Urol. Dec. 2005;12(12):1037-40. Case-series. [pmid: 16409606].
4923 Yakut M, Kaymakcioglu N, Simsek A, et al. Surgical treatment of rectal prolapse. A retrospective analysis of 94 cases. Int Surg. Jan–Mar. 1998;83(1):53-5. Case-series. [pmid: 9706519].
4924 Yalcin I, Bump RC. The effect of previous treatment experience and incontinence severity on the placebo response of stress urinary incontinence. Am J Obstet Gynecol. Jul. 2004;191(1):194-7. Not eligible exposure. [pmid: 15295364].
4925 Yalcin I, Patrick DL, Summers K, et al. Minimal clinically important differences in Incontinence Quality-of-Life scores in stress urinary incontinence. Urology. Jun. 2006;67(6):1304-8. Not eligible outcomes. [pmid: 16750246].
4926 Yalcin O, Isikoglu M, Beji NK. Results of TVT operations alone and combined with other vaginal surgical procedures. Arch Gynecol Obstet. Jan. 2004;269(2):96-8. Case-series. [pmid: 14648176].
4927 Yalcin OT, Hassa H, Ozalp S. Effectiveness of ultrasonographic parameters for documenting the severity of anatomic stress incontinence. Acta Obstet Gynecol Scand. May. 2000;79(5):421-6. Not eligible outcomes. [pmid: 10830771].
4928 Yalcin OT, Hassa H, Ozalp S, et al. Results of the anti-incontinence operations and Kegel exercises in patients with type II anatomic stress incontinence. Acta Obstet Gynecol Scand. Mar. 1998;77(3):341-6. Case-series. [pmid: 9539284].
4929 Yalcin OT, Hassa H, Tanir M. A new ultrasonographic method for evaluation of the results of anti-incontinence operations. Acta Obstet Gynecol Scand. Feb. 2002;81(2):151-6. Case-series. [pmid: 11942906].
4930 Yalcin OT, Yildirim A, Hassa H. The effects of severe cystocele on urogynecologic symptoms and findings. Acta Obstet Gynecol Scand. May. 2001;80(5):423-7. Case-series. [pmid: 11328218].
4931 Yamada T, Hayashi T, Kamata S, et al. New hammock hypothesis-based method for the treatment of stress urinary incontinence: the first 29 urethral supports with a small fascial patch. Int J Urol. Sep. 2005;12(9):806-9. Case-series. [pmid: 16201976].
4932 Yamada T, Ichiyanagi N, Kamata S, et al. Need for sling surgery in patients with large cystoceles and masked stress urinary incontinence. Int J Urol. Nov. 2001;8(11):599-603. Case-series. [pmid: 11903685].
4933 Yamada T, Kamata S, Nagahama K, et al. Polytetrafluoroethylene patch sling for type 2 or type 3 stress urinary incontinence. Int J Urol. Dec. 2001;8(12):675-80. Not eligible exposure. [pmid: 11851767].
4934 Yamada T, Mizuo T, Kawakami S, et al. Application of transrectal ultrasonography in modified Stamey procedure for stress urinary incontinence. J Urol. Dec. 1991;146(6):1555-8. Case-series. [pmid: 1942340].
4935 Yamada Y, Honda N, Nakamura K, et al. Vesicourethral anastomotic suture placement during radical prostatectomy using Maniceps. Urol Int. 2003;70(3):181-5. Case-series. [pmid: 12660454].
4936 Yamana T, Oya M, Komatsu J, et al. Preoperative anal sphincter high pressure zone, maximum tolerable volume, and anal mucosal electrosensitivity predict early postoperative defecatory function after low anterior resection for rectal cancer. Dis Colon Rectum. Sep. 1999;42(9):1145-51. Case-series. [pmid: 10496554].
4937 Yamana T, Takahashi T, Iwadare J. Clinical and physiologic outcomes after transvaginal rectocele repair. Dis Colon Rectum. May. 2006;49(5):661-7. Case-series. [pmid: 16680502].
4938 Yamanishi T, Yasuda K, Sakakibara R, et al. Detrusor overactivity and penile erection in patients with lower lumbar spine lesions. Eur Urol. Oct. 1998;34(4):360-4. Case-series. [pmid: 9748686].
4939 Yamanishi T, Yasuda K, Suda S, et al. Effect of functional continuous magnetic stimulation for urinary incontinence. J Urol. Feb. 2000;163(2):456-9. Not eligible target population. [pmid: 10647653].
4940 Yan A, Anne M, Karine A, et al. Cystocele repair by a synthetic vaginal mesh secured anteriorly through the obturator foramen. Eur J Obstet Gynecol Reprod Biol. Jul 15. 2004;115(1):90-4. Case-series. [pmid: 15223172].
4941 Yang CC, Stiens SA. Antegrade continence enema for the treatment of neurogenic constipation and fecal incontinence after spinal cord injury. Arch Phys Med Rehabil. May. 2000;81(5):683-5. Case Reports. [pmid: 10807111].
4942 Yang JM. Factors affecting urethrocystographic parameters in urinary continent women. J Clin Ultrasound. Jun. 1996;24(5):249-55. Not eligible outcomes. [pmid: 8723513].
4943 Yang JM, Huang WC. Discrimination of bladder disorders in female lower urinary tract symptoms on ultrasonographic cystourethrography. J Ultrasound Med. Nov. 2002;21(11):1249-55. Not eligible outcomes. [pmid: 12418766].
4944 Yang JM, Yang SH, Huang WC. Dynamic morphological changes in the anterior vaginal wall before and after laparoscopic Burch colposuspension in primary urodynamic stress incontinence. Ultrasound Obstet Gynecol. Mar. 2005;25(3):289-95. Case-series. [pmid: 15736202].
4945 Yang JM, Yang SH, Huang WC. A surgical technique to adjust bladder neck suspension in laparoscopic Burch colposuspension. J Minim Invasive Gynecol. Jul–Aug. 2006;13(4):289-95. Case-series. [pmid: 16825068].
4946 Yang T, Liu Z, Liu Y. Electroacupuncture at ciliao and huiyang for treating neuropathic incontinence of defecation and urination in 30 cases. J Tradit Chin Med. Mar. 2003;23(1):53-4. Case Reports. [pmid: 12747203].
4947 Yang YK, Wexner SD. Anal pressure vectography is of no apparent benefit for sphincter evaluation. Int J Colorectal Dis. May. 1994;9(2):92-5. Case-series. [pmid: 8064197].
4948 Yeni E, Unal D, Verit A, et al. An adult female epispadias without exstrophy was presented with urinary incontinence: a case report. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):212-3. Case Reports. [pmid: 15168004].
4949 Yeoh E, Sun WM, Russo A, et al. A retrospective study of the effects of pelvic irradiation for gynecological cancer on anorectal function. Int J Radiat Oncol Biol Phys. Jul 15. 1996;35(5):1003-10. Case-series. [pmid: 8751409].
4950 Yeoh EE, Botten R, Russo A, et al. Chronic effects of therapeutic irradiation for localized prostatic carcinoma on anorectal function. Int J Radiat Oncol Biol Phys. Jul 1. 2000;47(4):915-24. Case-series. [pmid: 10863060].
4951 Yeoh EE, Holloway RH, Fraser RJ, et al. Anorectal dysfunction increases with time following radiation therapy for carcinoma of the prostate. Am J Gastroenterol. Feb. 2004;99(2):361-9. Case-series. [pmid: 15046230].
4952 Yeoh EK, Russo A, Botten R, et al. Acute effects of therapeutic irradiation for prostatic carcinoma on anorectal function. Gut. Jul. 1998;43(1):123-7. Case-series. [pmid: 9771416]. [pmcid: 1727195].
4953 Yerkes EB, Cain MP, King S, et al. The Malone antegrade continence enema procedure: quality of life and family perspective. J Urol. Jan. 2003;169(1):320-3. Not eligible target population. [pmid: 12478181].
4954 Yerkes EB, Rink RC, Cain MP, et al. Use of a Monti channel for administration of antegrade continence enemas. J Urol. Oct. 2002;168(4 Pt 2):1883-5. discussion 5. Not eligible target population. [pmid: 12352382].
4955 Yerkes EB, Rink RC, King S, et al. Tap water and the Malone antegrade continence enema: a safe combination?. J Urol. Oct. 2001;166(4):1476-8. Not eligible target population. [pmid: 11547116].
4956 Yeung CK, Lund L. Laparoscopic cecostomy for anterior ectopic anus with constipation: a new and technical proposal. Eur J Pediatr Surg. Aug. 2000;10(4):276-7. Case Reports. [pmid: 11034520].
4957 Yeung CK, Sihoe JD, Sit FK, et al. Characteristics of primary nocturnal enuresis in adults: an epidemiological study. BJU Int. Feb. 2004;93(3):341-5. Not eligible outcomes. [pmid: 14764133].
4958 Yim SY, Yoon SH, Lee IY, et al. A comparison of bowel care patterns in patients with spinal cord injury: upper motor neuron bowel vs lower motor neuron bowel. Spinal Cord. Apr. 2001;39(4):204-7. Case-series. [pmid: 11420735].
4959 Yip B, Barrett RC, Coller JA, et al. Pudendal nerve terminal motor latency testing: assessing the educational learning curve: can we teach our own?. Dis Colon Rectum. Feb. 2002;45(2):184-7. Not eligible exposure. [pmid: 11852330].
4960 Yip B, Barrett RC, Coller JA, et al. Linear pressure profiles and symmetric findings in the stimulated gracilis muscle. Dis Colon Rectum. Jan. 2003;46(1):77-80. Case-series. [pmid: 12544525].
4961 Yip SK, Chung TK. Treatment-seeking behavior in Hong Kong Chinese women with urinary symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):27-30. discussion Not eligible level of evidence. [pmid: 12601513].
4962 Yip SK, Fung K, Pang MW, et al. A study of female urinary tract infection caused by urodynamic investigation. Am J Obstet Gynecol. May. 2004;190(5):1234-40. Not eligible outcomes. [pmid: 15167824].
4963 Yip SK, Leung TY, Chan CK. Hematuria and clot retention after Burch colposuspension and Cystofix suprapubic catheterization: suprapubic cystotomy as an alternative suprapubic drainage method. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(2):122-4. Case Reports. [pmid: 9694143].
4964 Yip SK, Pang MW. Tension-free vaginal tape sling procedure for the treatment of stress urinary incontinence in Hong Kong women with and without pelvic organ prolapse: 1-year outcome study. Hong Kong Med J. Feb. 2006;12(1):15-20. Not eligible target population. [pmid: 16495584].
4965 Yohannes P, Khan A, Francis K, et al. Robot-assisted Bricker ileoureteral anastomosis during intracorporeal laparoscopic ileal conduit urinary diversion for prostatocutaneous fistula: case report. J Endourol. Apr. 2004;18(3):269-72. Case Reports. [pmid: 15225393].
4966 Yokoo A, Hirose T, Mikuma N, et al. Ileal neobladder for bladder substitution after radical cystectomy. Int J Urol. May. 1998;5(3):219-24. Case-series. [pmid: 9624551].
4967 Yokoyama E. Contigen Bard Collagen implant: the Japanese experience. Int J Urol. Apr. 1995;2(Suppl 1):11-5. discussion 6–8. Not eligible target population. [pmid: 7614409].
4968 Yokoyama T, Fujita O, Nishiguchi J, et al. Extracorporeal magnetic innervation treatment for urinary incontinence. Int J Urol. Aug. 2004;11(8):602-6. Not eligible target population. [pmid: 15285749].
4969 Yokoyama T, Inoue M, Fujita O, et al. Preliminary results of the effect of extracorporeal magnetic stimulation on urinary incontinence after radical prostatectomy: a pilot study. Urol Int. 2005;74(3):224-8. Case-series. [pmid: 15812208].
4970 Yoo JH, Hasegawa H, Ishii Y, et al. Long-term outcome of per anum intersphincteric rectal dissection with direct coloanal anastomosis for lower rectal cancer. Colorectal Dis. Sep. 2005;7(5):434-40. Case-series. [pmid: 16108877].
4971 Yoshimura N, Nagahama Y, Ueda T, et al. Paroxysmal urinary incontinence associated with multiple sclerosis. Urol Int. 1997;59(3):197-9. Case- Reports. [pmid: 9428442].
4972 Yoshioka K, Keighley MR. The position of the patient does not adversely influence the results of the most clinically important measurements of anorectal function. Int J Colorectal Dis. 1995;10(1):47-8. Not eligible exposure. [pmid: 7745324].
4973 Young CJ, Mathur MN, Eyers AA, et al. Successful overlapping anal sphincter repair: relationship to patient age, neuropathy, and colostomy formation. Dis Colon Rectum. Mar. 1998;41(3):344-9. Case-series. [pmid: 9514430].
4974 Young MD, Weizer AZ, Silverstein AD, et al. Urinary continence and quality of life in the first year after radical perineal prostatectomy. J Urol. Dec. 2003;170(6 Pt 1):2374-8. Case-series. [pmid: 14634420].
4975 Young SB, Howard AE, Baker SP. Mersilene mesh sling: short- and long-term clinical and urodynamic outcomes. Am J Obstet Gynecol. Jul. 2001;185(1):32-40. Not eligible target population. [pmid: 11483900].
4976 Youngson HA, Alderman N. Fear of incontinence and its effects on a community-based rehabilitation programme after severe brain injury: successful remediation of escape behaviour using behaviour modification. Brain Inj. Jan. 1994;8(1):23-36. Case- Reports. [pmid: 8124314].
4977 Youssef AH, Fath-Alla M, El-Kassaby AW. Perineal subcutaneous dartos pedicled flap as a new technique for repairing urethrorectal fistula. J Urol. May. 1999;161(5):1498-500. Not eligible target population. [pmid: 10210381].
4978 Yu DS. Gelatin packing of intracortical tract after percutaneous nephrostomy lithotripsy for decreasing bleeding and urine leakage. J Chin Med Assoc. Apr. 2006;69(4):162-5. Case-series. [pmid: 16689197].
4979 Yu LC, Rohner TJ, Kaltreider DL, et al. Profile of urinary incontinent elderly in long-term care institutions. J Am Geriatr Soc. Apr. 1990;38(4):433-9. Not eligible target population. [pmid: 2109766].
4980 Yu YF, Nichol MB, Yu AP, et al. Persistence and adherence of medications for chronic overactive bladder/urinary incontinence in the california medicaid program. Value Health. Jul–Aug. 2005;8(4):495-505. Not eligible outcomes. [pmid: 16091027].
4981 Yusuf SW, Booth SA, Mishra RM. Falls and urinary incontinence in a 66-year-old woman. Lancet. Jun 22. 1996;347(9017):1738. Case report. [pmid: 8656908].
4982 Zahn CM, Siddique S, Hernandez S, et al. Anatomic comparison of two transobturator tape procedures. Obstet Gynecol. Mar. 2007;109(3):701-6. Not eligible target population. [pmid: 17329523].
4983 Zanoschi C, Carauleanu A. The use of the supra-pubic fibrous complex in isthmic hysteropexies. Rev Med Chir Soc Med Nat Iasi. Jul–Sep. 2003;107(3):627-32. Case-series. [pmid: 14756075].
4984 Zaragoza MR. Expanded indications for the pubovaginal sling: treatment of type 2 or 3 stress incontinence. J Urol. Nov. 1996;156(5):1620-2. Case-series. [pmid: 8863552].
4985 Zbar AP, Aslam M, Gold DM, et al. Parameters of the rectoanal inhibitory reflex in patients with idiopathic fecal incontinence and chronic constipation. Dis Colon Rectum. Feb. 1998;41(2):200-8. Not eligible outcomes. [pmid: 9556245].
4986 Zbar AP, Beer-Gabel M, Chiappa AC, et al. Fecal incontinence after minor anorectal surgery. Dis Colon Rectum. Nov. 2001;44(11):1610-9. discussion 9–23. Case-series. [pmid: 11711732].
4987 Zbar AP, Kmiot WA, Aslam M, et al. Use of vector volume manometry and endoanal magnetic resonance imaging in the adult female for assessment of anal sphincter dysfunction. Dis Colon Rectum. Nov. 1999;42(11):1411-8. Not eligible exposure. [pmid: 10566528].
4988 Zehrer CL, Newman DK, Grove GL, et al. Assessment of diaper-clogging potential of petrolatum moisture barriers. Ostomy Wound Manage. Dec. 2005;51(12):54-8. Not eligible outcomes.
4989 Zeidman LA, Melen O, Gottardi-Littell N, et al. Susac syndrome with transient inverted vision. Neurology. Aug 10. 2004;63(3):591. Case Reports. [pmid: 15304609].
4990 Zelefsky MJ, Aschkenasy E, Kelsen S, et al. Tolerance and early outcome results of postprostatectomy three-dimensional conformal radiotherapy. Int J Radiat Oncol Biol Phys. Sep 1. 1997;39(2):327-33. Case-series. [pmid: 9308935].
4991 Zemack G, Romner B. Adjustable valves in normal-pressure hydrocephalus: a retrospective study of 218 patients. Neurosurgery. Dec. 2002;51(6):1392-400. discussion 400–2. Not eligible target population. [pmid: 12445344].
4992 Zermann DH, Ishigooka M, Wunderlich H, et al. A study of pelvic floor function pre- and postradical prostatectomy using clinical neurourological investigations, urodynamics and electromyography. Eur Urol. Jan. 2000;37(1):72-8. Case-series. [pmid: 10671789].
4993 Zermann DH, Kutzenberger J, Sauerwein D, et al. Penile prosthetic surgery in neurologically impaired patients: long-term followup. J Urol. Mar. 2006;175(3 Pt 1):1041-4. discussion 4. Not eligible target population. [pmid: 16469612].
4994 Zetterstrom J, Lopez A, Holmstrom B, et al. Obstetric sphincter tears and anal incontinence: an observational follow-up study. Acta Obstet Gynecol Scand. Oct. 2003;82(10):921-8. Case-series. [pmid: 12956842].
4995 Zetterstrom J, Mellgren A, Jensen LL, et al. Effect of delivery on anal sphincter morphology and function. Dis Colon Rectum. Oct. 1999;42(10):1253-60. Case-series. [pmid: 10528760].
4996 Zetterstrom JP, Mellgren A, Madoff RD, et al. Perineal body measurement improves evaluation of anterior sphincter lesions during endoanal ultrasonography. Dis Colon Rectum. Jun. 1998;41(6):705-13. Not eligible outcomes. [pmid: 9645738].
4997 Z'Graggen K, Maurer CA, Birrer S, et al. A new surgical concept for rectal replacement after low anterior resection: the transverse coloplasty pouch. Ann Surg. Dec. 2001;234(6):780-5. discussion 5–7. Not eligible target population. [pmid: 11729384]. [pmcid: 1422137].
4998 Zhengwei Y, Weilin W, Yuzuo B, et al. Long-term outcomes of individualized biofeedback training based on the underlying dysfunction for patients with imperforate anus. J Pediatr Surg. Mar. 2005;40(3):555-61. Not eligible target population. [pmid: 15793735].
4999 Zhu L, Lang J, Chen J, et al. Study on nerve fiber density in anterior vaginal epithelium for stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):272-5. Not eligible outcomes. [pmid: 15517673].
5000 Zhu L, Lang J, Feng R, et al. Estrogen receptor in pelvic floor tissues in patients with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):340-3. Not eligible outcomes. [pmid: 15580421].
5001 Zhu L, Lang JH, Chen J, et al. Morphologic study on levator ani muscle in patients with pelvic organ prolapse and stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):401-4. Not eligible outcomes. [pmid: 16007351].
5002 Zhu L, Lang JH, Li Y, et al. Postoperative evaluation of tension-free vaginal tape procedure. Chin Med Sci J. Jun. 2005;20(2):116-8. Case-series. [pmid: 16075750].
5003 Zietman AL, Sacco D, Skowronski U, et al. Organ conservation in invasive bladder cancer by transurethral resection, chemotherapy and radiation: results of a urodynamic and quality of life study on long-term survivors. J Urol. Nov. 2003;170(5):1772-6. Case-series. [pmid: 14532773].
5004 Zimakoff J, Stickler DJ, Pontoppidan B, et al. Bladder management and urinary tract infections in Danish hospitals, nursing homes, and home care: a national prevalence study. Infect Control Hosp Epidemiol. Apr. 1996;17(4):215-21. Not eligible outcomes. [pmid: 8935728].
5005 Zimmaro Bliss D, Larson SJ, Burr JK, et al. Reliability of a stool consistency classification system. J Wound Ostomy Continence Nurs. Nov. 2001;28(6):305-13. Not eligible outcomes. [pmid: 11707763].
5006 Zimmaro Bliss D, Zehrer C, Savik K, et al. Incontinence-associated skin damage in nursing home residents: a secondary analysis of a prospective, multicenter study. Ostomy Wound Manage. Dec. 2006;52(12):46-55. Not eligible outcomes.
5007 Zincke H, Oesterling JE, Blute ML, et al. Long-term (15 years) results after radical prostatectomy for clinically localized (stage T2c or lower) prostate cancer. J Urol. Nov. 1994;152(5 Pt 2):1850-7. Not eligible level of evidence. [pmid: 7523733].
5008 Zinner N, Gittelman M, Harris R, et al. Trospium chloride improves overactive bladder symptoms: a multicenter phase III trial. J Urol. Jun. 2004;171(6 Pt 1):2311-5. quiz 435. Not eligible exposure. [pmid: 15126811].
5009 Zinner N, Harnett M, Sabounjian L, et al. The overactive bladder-symptom composite score: a composite symptom score of toilet voids, urgency severity and urge urinary incontinence in patients with overactive bladder. J Urol. May. 2005;173(5):1639-43. Not eligible exposure. [pmid: 15821526].
5010 Zinner N, Susset J, Gittelman M, et al. Efficacy, tolerability and safety of darifenacin, an M(3) selective receptor antagonist: an investigation of warning time in patients with OAB. Int J Clin Pract. Jan. 2006;60(1):119-26. Not eligible exposure. [pmid: 16409440].
5011 Zinner N, Tuttle J, Marks L. Efficacy and tolerability of darifenacin, a muscarinic M3 selective receptor antagonist (M3 SRA), compared with oxybutynin in the treatment of patients with overactive bladder. World J Urol. Sep. 2005;23(4):248-52. Not eligible exposure. [pmid: 16096831].
5012 Zinner NR, Mattiasson A, Stanton SL. Efficacy, safety, and tolerability of extended-release once-daily tolterodine treatment for overactive bladder in older versus younger patients. J Am Geriatr Soc. May. 2002;50(5):799-807. Not eligible exposure. [pmid: 12028164].
5013 Zivkovic F, Tamussino K, Pieber D, et al. Body mass index and outcome of incontinence surgery. Obstet Gynecol. May. 1999;93(5 Pt 1):753-6. Case-series. [pmid: 10912980].
5014 Zorcolo L, Covotta L, Bartolo DC. Outcome of anterior sphincter repair for obstetric injury: comparison of early and late results. Dis Colon Rectum. Mar. 2005;48(3):524-31. Case-series. [pmid: 15747083].
5015 Zorn BH, Montgomery H, Pieper K, et al. Urinary incontinence and depression. J Urol. Jul. 1999;162(1):82-4. Not eligible outcomes. [pmid: 10379745].
5016 Zubke W, Becker S, Kramer B, et al. Persistent urinary retention after tension-free vaginal tape: a new surgical solution. Eur J Obstet Gynecol Reprod Biol. Jul 15. 2004;115(1):95-8. Case Reports. [pmid: 15223173].
5017 Zullo MA, Plotti F, Bellati F, et al. Transurethral polydimethylsiloxane implantation: a valid option for the treatment of stress urinary incontinence due to intrinsic sphincter deficiency without urethral hypermobility. J Urol. Mar. 2005;173(3):898-902. Case-series. [pmid: 15711314].
5018 Zvosec DL, Smith SW, McCutcheon JR, et al. Adverse events, including death, associated with the use of 1,4-butanediol. N Engl J Med. Jan 11. 2001;344(2):87-94. Case Reports. [pmid: 11150358].
5019 Zweig S, Lawhorne L, Post R. Factors predicting mortality in rural elderly hospitalized for pneumonia. J Fam Pract. Feb. 1990;30(2):153-9. Not eligible outcomes. [pmid: 2299310].
5020 Zwergel U, Wullich B, Lindenmeir U, et al. Long-term results following transurethral resection of the prostate. Eur Urol. 1998;33(5):476-80. Not eligible level of evidence. [pmid: 9643667].