# Appendix B. Exact Search Strings

[underlined: Search Strategy]

The following data bases were searched:

- Med Line (PubMed)
- The Cochrane Database of Systematic Reviews
- The Cochrane Central Register of Controlled Trials
- Internet (www.google.com and www.scirus.com/srsapp) with the key words identical MeSH terms
- CINAHL
- Manual search of the references in articles to identify eligible studies published before 1990

The following MeSH terms and key words (in databases other than Medline) and their combinations were used to search the data bases from 1990 through March 2007:

Medical Subject Headings Terms

“Urinary incontinence”

“Fecal incontinence”

“Costs and cost analysis”

“Prevalence”

“Incidence”

“Spinal cord”

“Spinal cord injuries”

“Spinal cord neoplasms”

“Spinal cord ischemia”

“Cerebrovascular accident”

“Brain stem infarctions”

“Infarction, middle cerebral artery”

“Infarction, anterior cerebral artery”

“Urologic surgical procedures, male”

“Digestive system surgical procedures”

“Obstetric surgical procedures”

“Gynecologic surgical procedures”

“Ureteroscopy”

“Hysteroscopy”

“Sigmoidoscopy”

“Proctoscopy”

“Mediastinoscopy”

“Cystoscopy”

“Colonoscopy”

“Smoking”

“Lung diseases”

“Pulmonary disease”

“Pulmonary heart disease”

“Lung diseases, obstructive”

“Pulmonary disease, chronic obstructive”

“Cardiovascular diseases”

“Intestinal diseases”

“Obesity”

“Diabetes mellitus”

“Diabetes mellitus, Type 2”

“Diabetes mellitus, Type 1”

“Depressive disorder”

“Depression”

“Depression, postpartum”

“Long-term depression (physiology)”

“Dementia”

“Institutionalization”

“Menopause”

“Pregnancy complications”

“Prostatic neoplasms”

“Body mass index”

“Multiple sclerosis”

“Fibromyalgia”

“Prostatic hyperplasia”

“Uterine prolapse”

“Rectal prolapse”

“Cystocele”

“Caffeine”

“Parkinson disease”

“Primary prevention”

Tolterodine tartrate

“Health education”

“Behavior therapy”

“Biofeedback”

“Bladder retraining ”

“Kegel exercises”

Weight loss"

“Anti-obesity agents”

“Homosexuality, male”

“Predictive value of tests”

“Reproducibility of results”

“Anal Canal/surgery”

“Biocompatible Materials”

“Polyethylenes”

“Electric Stimulation Therapy”

[underlined: Exact Literature Search Strings]

Medical Subject Headings Terms and Key Words | Number of Retrieved References
Urinary incontinence/epidemiology" [MeSH] OR “urinary incontinence/prevention and control” [MeSH] | 2,125
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] | 1,307
Limits: adult: 19–44 years, middle aged: 45–64 years, middle aged + aged: 45+ years, aged: 65+ years, 80 and over: 80+ years, English, humans
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] | 59
Limits: adult: 19–44 years, middle aged: 45–64 years, middle aged + aged: 45+ years, Aged: 65+ years, 80 and over: 80+ years, English, randomized controlled trial, humans
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] | 845
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] | 398
Limits: adult: 19–44 years, middle aged: 45–64 years, middle aged + aged: 45+ years, aged: 65+ years, 80 and over: 80+ years, English, humans
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH]) | 15
Limits: adult: 19–44 years, middle aged: 45–64 years, middle aged + Aged: 45+ years, aged: 65+ years, 80 and over: 80+ years, English, randomized controlled trial, humans
“Costs and cost analysis” [MeSH] AND fecal incontinence | 30
Limits: adult, English, humans
“Costs and cost analysis” [MeSH] AND urinary incontinence | 162
Limits: adult English, humans
“Prevalence” [MeSH] AND fecal incontinence | 124
Limits: adult, English, humans
“Prevalence” [MeSH] AND urinary incontinence | 437
Limits: adult, English, humans
“Incidence” [MeSH] AND fecal incontinence | 73
Limits: adult, English, humans
“Incidence” [MeSH] AND urinary incontinence | 230
Limits: adult, English, humans
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] AND “costs and cost analysis” [MeSH] | 10
Limits: adult, English, humans
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] AND “prevalence” [MeSH] | 86
Limits: adult, English, humans
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] AND “incidence” [MeSH] | 39
Limits: adult, English, humans
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] AND “costs and cost analysis” [MeSH] | 49
Limits: adult, English, humans
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] AND “costs and cost analysis” [MeSH] | 71
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] AND “prevalence” [MeSH] | 343
Limits: adult, English, humans
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] AND “prevalence” [MeSH] | 460
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] AND “ incidence” [MeSH] | 228
“Urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH] AND “incidence” [MeSH] | 152
Limits: adult, English, humans
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] AND “costs and cost analysis” [MeSH] | 14
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] AND “prevalence” [MeSH] | 124
“Fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH] AND “incidence” [MeSH] | 58
Fecal incontinence AND (“spinal cord” [MeSH] OR “spinal cord injuries” [MeSH] OR “spinal cord neoplasms” [MeSH] OR “spinal cord ischemia” [MeSH]) | 88
Limits: adult, English, humans
Urinary incontinence AND (“spinal cord” [MeSH] OR “spinal cord injuries” [MeSH] OR “spinal cord neoplasms” [MeSH] OR “spinal cord ischemia” [MeSH]) | 195
Limits: adult, English, humans
Fecal incontinence AND (“cerebrovascular accident” [MeSH] OR “brain stem infarctions” [MeSH] OR “infarction, middle cerebral artery” [MeSH] OR “infarction, anterior cerebral artery” [MeSH]) | 10
Limits: adult, English, humans
Urinary incontinence AND (“cerebrovascular accident” [MeSH] OR “brain stem infarctions” [MeSH] OR “infarction, middle cerebral artery” [MeSH] OR “infarction, anterior cerebral artery” [MeSH]) | 77
Limits: adult, English, humans
Fecal incontinence AND (“urologic surgical procedures, male” [MeSH] OR “urologic surgical procedures” [MeSH] OR “digestive system surgical procedures” [MeSH] OR “obstetric surgical procedures” [MeSH] OR “gynecologic surgical procedures” [MeSH] OR “ureteroscopy” [MeSH] OR “hysteroscopy” [MeSH] OR “sigmoidoscopy” [MeSH] OR “proctoscopy” [MeSH] OR “mediastinoscopy” [MeSH] OR “cystoscopy” [MeSH] OR “colonoscopy” [MeSH]) | 566
Limits: adult, English, humans
Urinary incontinence AND (“urologic surgical procedures, male” [MeSH] OR “urologic surgical procedures” [MeSH] OR “digestive system surgical procedures” [MeSH] OR “obstetric surgical procedures” [MeSH] OR “gynecologic surgical procedures” [MeSH] OR “ureteroscopy” [MeSH] OR “hysteroscopy” [MeSH] OR “sigmoidoscopy” [MeSH] OR “proctoscopy” [MeSH] OR “mediastinoscopy” [MeSH] OR “cystoscopy” [MeSH] OR “colonoscopy” [MeSH]) | 1862
Limits: adult, English, humans
“Smoking” [MeSH] AND fecal incontinence | 1
Limits: adult, English, humans
“Smoking” [MeSH] AND urinary incontinence | 25
Limits: adult, English, humans
(“Lung diseases” [MeSH] OR “pulmonary disease (specialty)” [MeSH] OR “pulmonary heart disease” [MeSH] OR “lung diseases, obstructive” [MeSH] OR “pulmonary disease, chronic obstructive” [MeSH]) AND fecal incontinence | 6
Limits: adult, English, humans
(“Lung diseases” [MeSH] OR “pulmonary disease (specialty)” [MeSH] OR “pulmonary heart disease” [MeSH] OR “lung diseases, obstructive” [MeSH] OR “pulmonary disease, chronic obstructive” [MeSH]) AND urinary incontinence | 46
Limits: adult, English, humans
“Cardiovascular diseases” [MeSH] AND fecal incontinence | 135
Limits: adult, English, humans
“Cardiovascular diseases” [MeSH] AND urinary incontinence | 349
Limits: adult, English, humans
“Intestinal diseases” [MeSH] AND fecal incontinence | 2,531
Limits: adult, English, humans
“Intestinal diseases” [MeSH] AND urinary incontinence | 693
Limits: adult, English, humans
“Obesity” [MeSH] AND fecal incontinence | 9
Limits: adult, English, humans
“Obesity” [MeSH] AND urinary incontinence | 61
Limits: adult, English, humans
(“Diabetes mellitus” [MeSH] OR “diabetes mellitus, type 2” [MeSH] OR “diabetes mellitus, type 1” [MeSH]) AND fecal incontinence | 37
Limits: adult, English, humans
(“Diabetes mellitus” [MeSH] OR “diabetes mellitus, type 2” [MeSH] OR “diabetes mellitus, type 1” [MeSH]) AND urinary incontinence | 69
Limits: adult, English, humans
(“Depressive disorder” [MeSH] OR “depression” [MeSH] OR “depression, postpartum” [MeSH] OR “long-term depression (physiology)” [MeSH]) AND fecal incontinence | 26
Limits: adult, English, humans
(“Depressive disorder” [MeSH] OR “depression” [MeSH] OR “depression, postpartum” [MeSH] OR “long-term depression (physiology)” [MeSH]) AND urinary incontinence | 108
Limits: adult, English, humans
“Dementia” [MeSH] AND fecal incontinence | 26
Limits: adult, English, humans
“Dementia” [MeSH] AND urinary incontinence | 175
Limits: adult, English, humans
“Institutionalization” [MeSH] AND fecal incontinence | 11
Limits: adult, English, humans
“Institutionalization” [MeSH] AND urinary incontinence | 34
Limits: adult, English, humans
“Menopause” [MeSH] AND fecal incontinence | 16
Limits: adult, English, humans
“Menopause” [MeSH] AND urinary incontinence | 213
Limits: adult, English, humans
“Pregnancy complications” [MeSH] AND fecal incontinence | 133
Limits: adult, English, humans
“Pregnancy complications” [MeSH] AND urinary incontinence | 155
Limits: adult, English, humans
“Prostatic neoplasms” [MeSH] AND fecal incontinence | 39
Limits: adult, English, humans
“Prostatic neoplasms” [MeSH] AND urinary incontinence | 346
Limits: adult, English, humans
Urinary incontinence AND “prostatic neoplasms” [MeSH] NOT review NOT letter NOT editorial | 311
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “prostatic neoplasms” [MeSH] NOT review NOT letter NOT editorial | 37
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “pregnancy complications” [MeSH] NOT review NOT letter NOT editorial | 119
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND “pregnancy complications” [MeSH] NOT review NOT letter NOT editorial | 138
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND “menopause” [MeSH] NOT review NOT letter NOT editorial | 177
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “menopause” [MeSH] NOT review NOT letter NOT editorial | 15
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “institutionalization” [MeSH] NOT review NOT letter NOT editorial | 10
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND “institutionalization” [MeSH] NOT review NOT letter NOT editorial | 30
Limits: all adult: 19+ years, English, Humans
Urinary incontinence AND “dementia” [MeSH] NOT review NOT letter NOT editorial | 145
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “dementia” [MeSH] NOT review NOT letter NOT editorial | 24
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND (“depressive disorder” [MeSH] OR “depression” [MeSH] OR “depression, postpartum” [MeSH] OR “long-term depression (physiology)” [MeSH]) NOT review NOT letter NOT editorial | 26
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND (“depressive disorder” [MeSH] OR “depression” [MeSH] OR “depression, postpartum” [MeSH] OR “long-term depression (physiology)” [MeSH]) NOT review NOT letter NOT editorial | 85
Limits: all Adult: 19+ years, English, humans
Urinary incontinence AND (“diabetes mellitus” [MeSH] OR “diabetes mellitus, type 2” [MeSH] OR “diabetes mellitus, type 1” [MeSH]) NOT review NOT letter NOT editorial | 63
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND (“diabetes mellitus” [MeSH] OR “diabetes mellitus, type 2” [MeSH] OR “diabetes mellitus, type 1” [MeSH]) NOT review NOT letter NOT editorial | 34
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “obesity” [MeSH] NOT review NOT letter NOT editorial | 7
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND “obesity” [MeSH] NOT review NOT letter NOT editorial | 50
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND “intestinal diseases” [MeSH] NOT review NOT letter NOT editorial | 603
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “intestinal diseases” [MeSH] NOT review NOT letter NOT editorial | 2,229
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “cardiovascular Diseases” [MeSH] NOT review NOT letter NOT editorial | 118
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND “cardiovascular diseases” [MeSH] NOT review NOT letter NOT editorial | 286
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND (“lung diseases” [MeSH] OR “pulmonary disease (specialty)” [MeSH] OR “pulmonary heart disease” [MeSH] OR “lung diseases, obstructive” [MeSH] OR “pulmonary disease, chronic obstructive” [MeSH]) NOT review NOT letter NOT editorial | 34
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND (“lung diseases” [MeSH] OR “pulmonary disease (specialty)” [MeSH] OR “pulmonary heart disease” [MeSH] OR “lung diseases, obstructive” [MeSH] OR “pulmonary disease, chronic obstructive” [MeSH]) NOT review NOT letter NOT editorial | 5
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND “smoking” [MeSH] NOT review NOT letter NOT editorial | 0
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND “smoking” [MeSH] NOT review NOT letter NOT editorial | 23
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND (“urologic surgical procedures, male” [MeSH] OR “urologic surgical procedures” [MeSH] OR “digestive system surgical procedures” [MeSH] OR “obstetric surgical procedures” [MeSH] OR “gynecologic surgical procedures” [MeSH] OR “ureteroscopy” [MeSH] OR “hysteroscopy” [MeSH] OR “sigmoidoscopy” [MeSH] OR “proctoscopy” [MeSH] OR “mediastinoscopy” [MeSH] OR “cystoscopy” [MeSH] OR “colonoscopy” [MeSH]) NOT review NOT letter NOT editorial | 1669
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND (“urologic surgical procedures, male” [MeSH] OR “urologic surgical procedures” [MeSH] OR “digestive system surgical procedures” [MeSH] OR “obstetric surgical procedures” [MeSH] OR “gynecologic surgical procedures” [MeSH] OR “ureteroscopy” [MeSH] OR “hysteroscopy” [MeSH] OR “sigmoidoscopy” [MeSH] OR “proctoscopy” [MeSH] OR “mediastinoscopy” [MeSH] OR “cystoscopy” [MeSH] OR “colonoscopy” [MeSH]) NOT review NOT letter NOT editorial | 524
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND (“cerebrovascular accident” [MeSH] OR “brain stem infarctions” [MeSH] OR “infarction, middle cerebral artery” [MeSH] OR “infarction, anterior cerebral artery” [MeSH]) NOT review NOT letter NOT editorial | 6
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND (“cerebrovascular accident” [MeSH] OR “brain stem infarctions” [MeSH] OR “infarction, middle cerebral artery” [MeSH] OR “infarction, anterior cerebral artery” [MeSH]) NOT review NOT letter NOT editorial | 64
Limits: all adult: 19+ years, English, humans
Urinary incontinence AND (“spinal cord” [MeSH] OR “spinal cord injuries” [MeSH] OR “spinal cord neoplasms” [MeSH] OR “spinal cord ischemia” [MeSH]) NOT review NOT letter NOT editorial | 167
Limits: all adult: 19+ years, English, humans
Fecal incontinence AND (“spinal cord” [MeSH] OR “spinal cord injuries” [MeSH] OR “spinal cord neoplasms” [MeSH] OR “spinal cord ischemia” [MeSH]) NOT review NOT letter NOT editorial | 78
Limits: all adult: 19+ years, English, humans
“Costs and cost analysis” [MeSH] AND (“fecal incontinence/diagnosis” [MeSH] OR “fecal Incontinence/epidemiology” [MeSH] OR “fecal incontinence/ etiology” [MeSH] OR “fecal incontinence/prevention and control” [MeSH]) NOT review NOT letter NOT editorial | 16
Limits: all adult: 19+ years, English, humans
“Costs and cost analysis” [MeSH] AND (“urinary incontinence/diagnosis” [MeSH] OR “urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/ etiology” [MeSH] OR “urinary incontinence/prevention and control” [MeSH]) NOT review NOT letter NOT editorial | 57
Limits: all adult: 19+ years, English, humans
“Costs and cost analysis” [MeSH] | 25,982
Limits: all adult: 19+ years, English, humans
“Incidence” [MeSH] AND urinary incontinence NOT review NOT letter NOT editorial | 180
Limits: all adult: 19+ years, English, humans
“Incidence” [MeSH] AND fecal incontinence NOT review NOT letter NOT editorial | 65
Limits: all adult: 19+ years, English, humans
“Prevalence” [MeSH] AND urinary incontinence NOT review NOT letter NOT editorial | 358
Limits: all adult: 19+ years, English, humans
“Prevalence” [MeSH] AND fecal incontinence NOT review NOT letter NOT editorial | 104
Limits: all adult: 19+ years, English, humans
“Costs and cost analysis” [MeSH] AND urinary incontinence NOT review NOT letter NOT editorial | 128
Limits: all adult: 19+ years, English, humans
“Costs and cost analysis” [MeSH] AND fecal incontinence NOT review NOT letter NOT editorial | 26
Limits: all adult: 19+ years, English, humans
(“Fecal incontinence/diagnosis” [MeSH] OR “fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/etiology” [MeSH] OR “fecal incontinence/ prevention and control” [MeSH]) NOT review NOT letter NOT editorial | 1,436
(“Fecal incontinence/diagnosis” [MeSH] OR “fecal incontinence/epidemiology” [MeSH] OR “fecal incontinence/etiology” [MeSH] OR “fecal incontinence/ prevention and control” [MeSH]) | 1,635
Limits: all adult: 19+ years, English, humans
(“Urinary incontinence/diagnosis” [MeSH] OR “urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/etiology” [MeSH] OR “urinary incontinence/ prevention and control” [MeSH]) NOT review NOT letter NOT editorial | 3,815
Limits: all adult: 19+ years, English, humans
(“Urinary incontinence/diagnosis” [MeSH] OR “urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/etiology” [MeSH] OR “urinary Incontinence/ prevention and control” [MeSH]) | 4,470
Limits: all adult: 19+ years, English, humans
(“Urinary incontinence/diagnosis” [MeSH] OR “urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/etiology” [MeSH] OR “urinary incontinence/ prevention and control” [MeSH]) | 6,966
Limits: English, humans
(“Urinary incontinence/diagnosis” [MeSH] OR “urinary incontinence/epidemiology” [MeSH] OR “urinary incontinence/etiology” [MeSH] OR “urinary incontinence/ prevention and control” [MeSH]) | 9,492
(“Urinary incontinence” [MeSH] OR “urinary incontinence, urge” [MeSH] OR “urinary incontinence, stress” [MeSH]) AND “primary prevention” [MeSH] NOT review NOT letter NOT editorial | 6
Limits: all adult: 19+ years, English, humans
(“Urinary incontinence” [MeSH] OR “urinary incontinence, urge” [MeSH] OR “urinary incontinence, stress” [MeSH]) AND “primary prevention” [MeSH] | 12
Limits: all adult: 19+ years, English, humans
(“Urinary incontinence” [MeSH] OR “urinary incontinence, urge” [MeSH] OR “urinary incontinence, stress” [MeSH]) AND “primary prevention” [MeSH] | 29
“Primary prevention” [MeSH] AND fecal incontinence | 1
Limits: all adult: 19+ years, English, randomized controlled trial, humans
“Primary prevention” [MeSH] AND urinary incontinence | 1
Limits: all adult: 19+ years, English, randomized controlled trial, humans
“Primary prevention” [MeSH] | 83,315
“Fecal incontinence” [MeSH] AND “primary prevention” [MeSH] | 1
Limits: all adult: 19+ years, English, randomized controlled trial, humans
“Fecal incontinence” [MeSH] | 99
Limits: all adult: 19+ years, English, randomized controlled trial, humans
(“Urinary incontinence” [MeSH] OR “urinary incontinence, urge” [MeSH] OR “urinary incontinence, stress” [MeSH]) AND “primary prevention” [MeSH] | 1
Limits: all adult: 19+ years, English, randomized controlled trial, humans
(“Urinary incontinence” [MeSH] OR “urinary incontinence, urge” [MeSH] OR “urinary incontinence, stress” [MeSH]) | 18,254
Tolterodine tartrate | 307
“Fecal incontinence” [MeSH] | 268
Limits: all adult: 19+ years, English, clinical trial, randomized controlled trial, “clinical trial, phase I”, “clinical trial, phase II”, “clinical trial, phase III”, “clinical trial, phase IV”, controlled clinical trial, multicenter study, humans
“Urinary incontinence” [MeSH] | 1,077
Limits: all adult: 19+ years, English, clinical trial, randomized controlled trial, “clinical trial, phase I”, “clinical trial, phase II”, “clinical trial, phase III”, “clinical trial, phase IV”, controlled clinical trial, multicenter study, humans
“Urinary incontinence” [MeSH] | 8,007
Limits: all adult: 19+ years, English, humans
“Health education” [MeSH] AND “urinary incontinence” NOT review NOT letter NOT editorial | 133
Limits: all adult: 19+ years, English, humans
“Health education” [MeSH] | 23,976
Limits: all adult: 19+ years, English, humans
“Behavior therapy” [MeSH] AND “urinary incontinence” NOT review NOT letter NOT editorial | 194
Limits: all adult: 19+ years, English, humans
“Behavior therapy” [MeSH] | 13,495
Limits: all adult: 19+ years, English, humans
“Biofeedback” AND “urinary incontinence” NOT review NOT letter NOT editorial | 126
Limits: all adult: 19+ years, English, humans
“Bladder retraining” AND “urinary incontinence” NOT review NOT letter NOT editorial | 26
Limits: all adult: 19+ years, English, humans
“Kegel exercises” AND “urinary incontinence” NOT review NOT letter NOT editorial | 13
Limits: all adult: 19+ years, English, humans
Incontinence AND (“weight loss” [MeSH] OR “anti-obesity agents” [MeSH]) | 5
Limits: all adult: 19+ years, English, randomized controlled trial, humans
Incontinence AND “weight loss” | 3
Limits: all adult: 19+ years, English, randomized controlled trial, humans
“Fecal incontinence/diagnosis” [MeSH] | 43
Limits: all adult: 19+ years, English, clinical trial, randomized controlled trial, humans
“Fecal incontinence/diagnosis” [MeSH] | 817
“Urinary incontinence/diagnosis” [MeSH] | 143
Limits: all adult: 19+ years, English, clinical trial, randomized controlled trial, humans
“Fecal incontinence” [MeSH] AND “homosexuality, male” [MeSH] | 1
“Fecal incontinence” [MeSH] | 5,420
“Homosexuality, male” [MeSH] | 4,303
“Urinary incontinence” [MeSH] AND “predictive value of tests” [MeSH] NOT review NOT letter NOT comment | 122
Limits: all adult: 19+ years, English, humans
“Urinary incontinence” [MeSH] AND “predictive value of tests” [MeSH] | 136
Limits: all adult: 19+ years, English, humans
“Urinary incontinence” [MeSH] | 8,216
Limits: all adult: 19+ years, English, humans
“Fecal incontinence” [MeSH] AND “predictive value of tests” [MeSH] NOT review NOT letter NOT comment | 34
Limits: all adult: 19+ years, English, humans
“Fecal incontinence” [MeSH] AND “predictive value of tests” [MeSH] | 48
“Predictive value of tests” [MeSH] | 72,697
“Urinary incontinence/diagnosis” [MeSH] | 18
Limits: all adult: 19+ years, English, validation studies, humans
“Fecal incontinence/diagnosis” [MeSH] | 0
Limits: all adult: 19+ years, English, validation studies, humans
“Fecal incontinence/diagnosis” [MeSH] | 348
Limits: all adult: 19+ years, English, humans
“Reproducibility of results” [MeSH] AND “urinary incontinence” [MeSH] NOT review NOT letter NOT comment | 148
Limits: all adult: 19+ years, English, humans
“Reproducibility of results” [MeSH] AND “fecal incontinence” [MeSH] NOT review NOT letter NOT comment | 45
Limits: all adult: 19+ years, English, humans
“Reproducibility of results” [MeSH] AND “fecal incontinence” [MeSH] | 47
Limits: all adult: 19+ years, English, humans
“Reproducibility of results” [MeSH] | 45,118
Limits: all adult: 19+ years, English, humans
Hormone AND incontinence | 39
Limits: all adult: 19+ years, English, randomized controlled trial, female, humans
“Parkinson disease” [MeSH] AND “fecal incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 4
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Parkinson disease” [MeSH] AND “urinary incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 12
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Parkinson disease” [MeSH] | 9,932
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Caffeine” [MeSH] AND “fecal incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 0
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Caffeine” [MeSH] AND “urinary incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 5
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, Humans
“Caffeine” [MeSH] | 1,832
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
(“Uterine prolapse” [MeSH] OR “rectal prolapse” [MeSH] OR “cystocele” [MeSH]) AND “fecal incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 105
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
(“Uterine prolapse” [MeSH] OR “rectal prolapse” [MeSH] OR “cystocele” [MeSH]) AND “urinary incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 265
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
(“Uterine prolapse” [MeSH] OR “rectal prolapse” [MeSH] OR “vystocele” [MeSH]) | 1,341
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Prostatic hyperplasia” [MeSH] AND “fecal incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 0
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Prostatic hyperplasia” [MeSH] AND “urinary incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 47
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Prostatic hyperplasia” [MeSH] | 3,980
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Fibromyalgia” [MeSH] AND “fecal incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 0
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Fibromyalgia” [MeSH] AND “urinary incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 1
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Fibromyalgia” [MeSH] | 1,416
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Fecal incontinence” [MeSH] AND “multiple sclerosis” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 12
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Multiple sclerosis” [MeSH] AND “urinary incontinence” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 23
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Multiple sclerosis” [MeSH] | 7,758
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Fecal incontinence” [MeSH] AND “body mass index” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 5
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Urinary incontinence” [MeSH] AND “body mass index” [MeSH] NOT review NOT comment NOT case-reports NOT letter | 74
Limits: all adult: 19+ years, English, publication date from 1990/01/01 to 2007/07/31, humans
“Body mass index” [MeSH] | 32,517
“Anal Canal/surgery”[MeSH] AND fecal continence Limits: Entrez Date from 1990/01/01 to 2007/08/31, English, Clinical Trial, Randomized Controlled Trial, Humans | 34
gracilis transposition AND fecal continence Limits: English, Clinical Trial, Randomized Controlled Trial, Multicenter Study, Humans | 2
Fecal incontinence AND (“Biocompatible Materials”[MeSH] OR “Biocompatible Materials”[Pharmacological Action] OR “Polyethylenes”[MeSH]) Limits: All Adult: 19+ years, English, Clinical Trial, Randomized Controlled Trial, Multicenter Study, Humans | 2
Sacral nerve stimulation AND fecal Limits: All Adult: 19+ years, English, Clinical Trial, Randomized Controlled Trial, Multicenter Study, Humans | 18
“Electric Stimulation Therapy”[MeSH] AND fecal Limits: All Adult: 19+ years, English, Clinical Trial, Randomized Controlled Trial, Multicenter Study, Humans | 27
“Colostomy”[MeSH] AND fecal incontinence Limits: All Adult: 19+ years, English, Clinical Trial, Randomized Controlled Trial, Multicenter Study, Humans | 9
“Colorectal Neoplasms”[Mesh] AND “fecal continence” Limits: published in the last 10 years, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 2
“Colorectal Neoplasms”[Mesh] AND “fecal incontinence” Limits: published in the last 10 years, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 12
“Colorectal Neoplasms”[Mesh] Limits: published in the last 10 years, Humans, Randomized Controlled Trial, English, All Adult: 19+ years | 959
“Colorectal Neoplasms” [Mesh] | 95,866
“Fecal Incontinence”[Mesh] AND “Proctocolectomy, Restorative”[Mesh] Limits: published in the last 10 years, Humans, Randomized Controlled Trial, Controlled Clinical Trial, Multicenter Study, English, All Adult: 19+ years | 9
“Fecal Incontinence”[Mesh] Limits: Humans, Clinical Trial, Randomized Controlled Trial, Controlled Clinical Trial, Multicenter Study, All Adult: 19+ years | 305
“Proctocolectomy, Restorative”[Mesh] Limits: Humans, Clinical Trial, Randomized Controlled Trial, Controlled Clinical Trial, Multicenter Study, All Adult: 19+ years | 123
Coloanal anastomoses AND fecal incontinence Limits: Humans, Clinical Trial, Randomized Controlled Trial, Controlled Clinical Trial, Multicenter Study, All Adult: 19+ years | 2
Coloanal anastomoses AND fecal incontinence | 18
Coloanal anastomoses | 85

Manual search of Cochrane review on treatment options for fecal incontinence

Source: Cochrane Incontinence Group reviews.

Topic. Nonsurgical therapy for anal fissure (Review)

Reference: Nelson R. Nonsurgical therapy for anal fissure

Cochrane Database Syst Rev. 2006 Oct 18;(4):CD003431. Review

PMID: 17054170

Analysis 02.02. Comparison 02 GTN or IDN versus sphincterotomy, Outcome 02 Minor Incontinence

Review: Non surgical therapy for anal fissure

Comparison: 02 GTN or IDN versus sphincterotomy

Outcome: 02 Minor Incontinence

| GTN | | LIS
| n | N | n | N
Evans 2001 | 0 | 34 | 2 | 31
Libertiny 2002 | 0 | 35 | 1 | 35
Mishra 2005 | 0 | 20 | 3 | 20
x Oettle 1997 | 0 | 12 | 0 | 12
Parellada 2004 | 0 | 27 | 4 | 27
Richard 2000 | 7 | 34 | 3 | 33

Analysis 08.02. Comparison 08 Botox versus sphincterotomy, Outcome 02 Minor Incontinence

Review: Nonsurgical therapy for anal fissure

Comparison: 08 Botox versus sphincterotomy

Outcome: 02 Minor Incontinence

Analysis 08.02. Comparison 08 Botox versus sphincterotomy, Outcome 02 Minor Incontinence

| Botox low dose | | Botox high dose
| n | N | n | N
Arroyo 2005 | 0 | 40 | 2 | 40
Mentes 2001 | 0 | 61 | 8 | 50

Topic. Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults.

Reference: Norton C, Cody JD, Hosker G. Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults. Cochrane Database Syst Rev. 2006 Jul 19;3:CD002111. Review. PMID: 16855987

Analysis 03.01. Comparison 03 BIOFEEDBACK ALONE versus NO TREATMENT, Outcome 01 Number of people failing to achieve full continence (worse, unchanged or improved)

Review: Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults

Comparison: 03 BIOFEEDBACK ALONE versus NO TREATMENT

Outcome: 01 Number of people failing to achieve full continence (worse, unchanged or improved)

| Exercises or BFB | | No exercises or BFB
| n | N | n | N
Miner 1990 | 9 | 13 | 12 | 12

Analysis 03.02. Comparison 03 BIOFEEDBACK ALONE versus NO TREATMENT, Outcome 02 Number of people with no improvement in incontinence status (worse or unchanged)

Review: Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults

Comparison: 03 BIOFEEDBACK ALONE versus NO TREATMENT

Outcome: 02 Number of people with no improvement in incontinence status (worse or unchanged)

| Exercises or BFB | | No exercises or BFB
| n | N | n | N
Miner 1990 | 2 | 13 | 7 | 12

Analysis 03.04. Comparison 03 BIOFEEDBACK ALONE versus NO TREATMENT, Outcome 04 Number of incontinence episodes per week

Review: Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults

Comparison: 03 BIOFEEDBACK ALONE versus NO TREATMENT

Outcome: 04 Number of incontinence episodes per week

| | Exercises or BFB | | | No exercises or BFB
| N | Mean | STD | N | Mean | STD
Miner 1990 | 13 | 0.9 | 0.08 | 12 | 2.3 | 0.17

Analysis 06.01. Comparison 06 ANAL SPHINCTER EXERCISES/PELVIC FLOOR MUSCLE TRAINING AND BIOFEEDBACK versus ANY OTHER TREATMENT, Outcome 01 Number of people failing to achieve full continence (worse, unchanged or improved)

Review: Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults

Comparison: 06 ANAL SPHINCTER EXERCISES/PELVIC FLOOR MUSCLE TRAINING AND BIOFEEDBACK versus ANY OTHER TREATMENT

Outcome: 01 Number of people failing to achieve full continence (worse, unchanged or improved)

| Exercises or BFB | | No exercises or BFB
| n | N | n | N
Fynes 1999 | 12 | 19 | 5 | 20

Analysis 06.02. Comparison 06 ANAL SPHINCTER EXERCISES/PELVIC FLOOR MUSCLE TRAINING AND BIOFEEDBACK versus ANY OTHER TREATMENT, Outcome 02 Number of people with no improvement in incontinence status (worse or unchanged)

Review: Biofeedback and/or sphincter exercises for the treatment of faecal incontinence in adults

Comparison: 06 ANAL SPHINCTER EXERCISES/PELVIC FLOOR MUSCLE TRAINING AND BIOFEEDBACK versus ANY OTHER TREATMENT

Outcome: 02 Number of people with no improvement in incontinence status (worse or unchanged)

| Exercises or BFB | | No exercises or BFB
| n | N | n | N
Fynes 1999 | 8 | 19 | 0 | 20

Topic: Drug treatment for faecal incontinence in adults.

Reference: Cheetham M, Brazzelli M, Norton C, Glazener CM Drug treatment for faecal incontinence in adults.

Cochrane Database Syst Rev. 2003;(3):CD002116.

No summary tables.

1 reference was excluded from our analysis as non RCT: Kusunoki M, Shoji Y, Ikeuchi H, Yamagata K, Yamamura T, Utsunomiya J. Usefulness of valproate sodium for treatment of incontinence after ileoanal anastomosis. Surgery. 1990 Mar;107(3):311–5.

Topic: Electrical stimulation for faecal incontinence in adults.

Reference: Hosker G, Norton C, Brazzelli M. Electrical stimulation for faecal incontinence in adults. Cochrane Database Syst Rev. 2000;(2):CD001310.

References to studies included in this review:

Fynes 1999 - included in our analysis

Fynes MM, Marshall K, Cassidy M, Behan M, Walsh D, O'Connell PR, O'Herlihy C. A prospective, randomized study comparing the effect of augmented biofeedback with sensory biofeedback alone on fecal incontinence after obstetric trauma. Diseases of the Colon and Rectum 1999;42(6):753–8; discussion 758–61. [MedLine: 99304944]

Topic: Management of faecal incontinence and constipation in adults with central neurological diseases.

Reference: Coggrave M, Wiesel PH, Norton C. Management of faecal incontinence and constipation in adults with central neurological diseases. Cochrane Database Syst Rev. 2006 Apr 19;(2):CD002115. Review.

PMID: 16625555

No studies reported fecal incontinence as an outcomes.

Analysis 01.34. Comparison 01 CISAPRIDE versus PLACEBO, Outcome 34 Number of bowel motions or successes bowel care routine per week

Review: Management of faecal incontinence and constipation in adults with central neurological diseases

Comparison: 01 CISAPRIDE versus PLACEBO

Outcome: 34 Number of bowel motions or successes bowel care routine per week

| Mean difference (95% CI)
Badiali 1991 | -0.5 (-2.26; 1.26)
de Both 1992 | -0.1 (-1; 0.8)
Total (95% CI) | -0.18 (-0.99; 0.62)

Analysis 01.35. Comparison 01 CISAPRIDE versus PLACEBO, Outcome 35 Ease of evacuation or straining effort (score)

Review: Management of faecal incontinence and constipation in adults with central neurological diseases

Comparison: 01 CISAPRIDE versus PLACEBO

Outcome: 35 Ease of evacuation or straining effort (score)

| Mean difference (95% CI)
Badiali 1991 | 0.6 (-0.18; 1.38)
de Both 1992 | -0.1 (-0.51; 0.31)
Total (95% CI) | 0.05 (-0.31; 0.42)

Analysis 01.36. Comparison 01 CISAPRIDE versus PLACEBO, Outcome 36 Oro-anal transit time (hours)

Review: Management of faecal incontinence and constipation in adults with central neurological diseases

Comparison: 01 CISAPRIDE versus PLACEBO

Outcome: 36 Oro-anal transit time (hours)

| Mean difference (95% CI)
Badiali 1991 | 10 (-19.01; 39.01)
de Both 1992 | 19.2 (-38.23; 76.63)
Total (95% CI) | 11.87 (-14.02; 37.76)

Authors' conclusions: “There is still remarkably little research on this common and, to patients, very significant condition. It is not possible to draw any recommendation for bowel care in people with neurological diseases from the trials included in this review. Bowel management for these people must remain empirical until well-designed controlled trials with adequate numbers and clinically relevant outcome measures become available”.

Topic: Operative procedures for fissure in ano.

Reference: Nelson R. Operative procedures for fissure in ano.

Cochrane Database Syst Rev. 2005 Apr 18;(2):CD002199. Review.

PMID: 15846630

The review included the studies with minor incontinence to flatus only.

Analysis 01.01. Comparison 01 Anal Stretch and partial internal sphincterotomy, Outcome 01 Persistence of the anal fissure

Review: Operative procedures for fissure in ano

Comparison: 01 Anal Stretch and partial internal sphincterotomy

Outcome: 01 Persistence of the anal fissure

| Anal Stretch | | Sphincterotomy | | Peto Odds Ratio (95% CI)
| n | N | n | N
Fischer 1976 | 3 | 34 | 1 | 32 | 2.68 (0.36; 19.96)
Jensen 1984 | 8 | 28 | 1 | 30 | 6.63 (1.62; 27.17)
Marby 1979 | 3 | 41 | 10 | 45 | 0.32 (0.1; 1.03)
Olsen 1987 | 3 | 10 | 1 | 10 | 3.28 (0.39; 27.75)
Saad 1992 | 3 | 37 | 2 | 20 | 0.79 (0.12; 5.33)
Weaver 1987 | 3 | 59 | 2 | 39 | 0.99 (0.16; 6.17)
Total (95% CI) | 209 | | 176 | | (.66; 2.48)

Analysis 01.02. Comparison 01 Anal Stretch and partial internal sphincterotomy, Outcome 02 Minor incontinence to flatus

Review: Operative procedures for fissure in ano

Comparison: 01 Anal Stretch and partial internal sphincterotomy

Outcome: 02 Minor incontinence to flatus

| Anal Stretch | | Sphincterotomy | | Peto Odds Ratio (95% CI)
| n | N | n | N
Fischer 1976 | 6 | 34 | 0 | 32 | 8.19 (1.55; 43.35)
Jensen 1984 | 8 | 28 | 0 | 30 | 10.61 (2.41; 46.62)
Marby 1979 | 0 | 41 | 0 | 45 | Not estimable
Olsen 1987 | 2 | 10 | 1 | 10 | 1 (0.12; 8.46)
Saad 1992 | 8 | 37 | 1 | 20 | 3.41 (0.78; 14.98)
Weaver 1987 | 0 | 59 | 2 | 39 | 0.08 (0; 4.44)
Total (95% CI) | 209 | | 176 | | 4.22 (1.89; 9.41)

Analysis 02.02. Comparison 02 Open versus closed partial lateral internal sphincterotomy, Outcome 02

Minor incontinence to flatus

Review: Operative procedures for fissure in ano

Comparison: 02 Open versus closed partial lateral internal sphincterotomy

Outcome: 02 Minor incontinence to flatus

| Open LIS | | Closed LIS | | Peto Odds Ratio (95% CI)
| n | N | n | N
Arroyo 2004 | 2 | 40 | 1 | 40 | 1.98 (0.2; 19.62)
Boulos 1984 | 2 | 14 | 3 | 14 | 0.63 (0.09; 4.18)
Kortbeek 1992 | 4 | 54 | 5 | 58 | 0.85 (0.22; 3.3)
Wiley 2002 | 2 | 40 | 3 | 36 | 0.59 (0.1; 3.56)
Total (95% CI) | 148 | | 148 | | 0.83 (0.35; 1.97)

Topic: Surgery for complete rectal prolapse in adults.

Reference: Bachoo P, Brazzelli M, Grant A. Surgery for complete rectal prolapse in adults. Cochrane Database Syst Rev. 2000;(2):CD001758. Review.

PMID: 10796817

McKee 1992 added to the review

Galili 1997 added to the review

Novell 1994 added to the review

Topic: Plugs for containing faecal incontinence.

Reference: Deutekom M, Dobben A. Plugs for containing faecal incontinence. Cochrane Database Syst Rev. 2005 Jul 20;(3):CD005086.

PMID: 16034966

Analysis 01.04. Comparison 01 Anal plugs versus no plugs, Outcome 04 Condition specific measures of faecal incontinence improved

Review: Plugs for containing faecal incontinence

Comparison: 01 Anal plugs versus no plugs

Outcome: 04 Condition specific measures of faecal incontinence improved

Based on unpublished data:

Bond 2005unpublished data only'

Bond C. The anal plug: an evaluation of a novel management option for faecal incontinence. Final report to Chief Scientist Office, Scottish

Executive Health Department, Edinburgh 2005.

Analysis 01.07. Comparison 01 Anal plugs versus no plugs, Outcome 07 Achievement of pseudo-continence

Achievement of pseudo-continence

Study Anal plug period Control period

Analysis 02.01. Comparison 02 One type of anal plug versus another type, Outcome 01 Plug effectiveness: number of people with no soiling

Plug effectiveness: number of people with no soiling

Study PU plug PVA plug

Van Winckel 2005 unpublished data only'

Van Winckel M. Clinical evaluation of a new anal medical device to achieve faecal continence in spina bi_da and anal atresia patients.

personal communication 2005.

VanWinckel M, Van Biervliet S, Van Laecke E, Hoebeke P. Is an anal plug useful in the treatment of fecal incontinence in children with spina bi_da or anal atresia?. Journal of Urology 2006;176(1):342{4. [MedLine: 22027].

Topic: Methods of repair for obstetric anal sphincter injury

Reference: Fernando R, Sultan AH, Kettle C, Thakar R, Radley S. Methods of repair for obstetric anal sphincter injury.

Cochrane Database Syst Rev. 2006 Jul 19;3:CD002866.

No additional published references identified.

Topic: Sacral nerve stimulation for faecal incontinence in adults(protocol only).

Topic: Surgery for faecal incontinence in adults.

Reference: Brown S, Nelson R. Surgery for faecal incontinence in adults.

Cochrane Database Syst Rev. 2007 Apr 18;2:CD001757.

PMID: 17443511

All references included in our review.