# Appendix A. Analytic Framework

Appendix D contains details on analytical framework of the report: algorithm to define eligibility of the studies, definitions, hypotheses, and statistical models.

Conceptual and operational definitions of incontinence and risk factors of incontinence are presented below.

## Conceptual Definitions

Fecal Incontinence—failure of voluntary control of the anal sphincters, with involuntary passage of feces and flatus (solid and liquid) and flatus ^1^

Urinary Incontinence—complaint of any involuntary leakage of urine ^2^

Urge urinary incontinence—involuntary urine leakage accompanied by or immediate preceded by urgency, usually related to the involuntary contractions of the detrusor muscle of the bladder (detrusor overactivity) ^2^

Stress Urinary Incontinence—involuntary urine leakage as a result of physical effort or exertion that increases abdominal pressure on the urinary bladder in the absence of detrusor contraction ^2^

Table 1 Operational definitions of incontinence

Variable | Definition
Symptoms of Urinary incontinence ^2^ | The complaint of any involuntary leakage of urine.
Signs of urinary Incontinence. | Urine leakage seen during examination: this may be urethral or extraurethral.
Extra-urethral incontinence | The observation of urine leakage through channels other than the urethra.
Uncategorized incontinence | The observation of involuntary leakage that cannot be classified into one of the above categories on the basis of signs and symptoms
Transient urinary incontinence ^3,^ ^4^ | A potentially reversible incontinence due to conditions that may resolve if the underlying cause is managed. These conditions include: delirium/confusional state; infection—urinary (symptomatic); atrophic urethritis/vaginitis; pharmaceuticals use; psychological conditions, especially depression; excessive urine output (e.g., CHF, hyperglycemia); restricted mobility; stool impaction
Established urinary incontinence ^3,^ ^4^ | Urinary incontinence that is attributed to bladder or urethral dysfunction such as: detrusor overactivity; detrusor underactivity; urethral obstruction; urethral incompetence
Stress urinary incontinence | Complaint of involuntary urine leakage on effort or exertion, or in sneezing or coughing
Urge urinary incontinence | Complaint of involuntary leakage accompanied by or immediately preceded by urgency
Overflow incontinence ^5^ | Urinary incontinence associated with: bladder overdistention; a contractile detrusor; hypotonic or underactive detrusor secondary to drugs, fecal impaction, diabetes, lower spinal cord injury, or disruption of the motor innervation of the detrusor muscle
Mixed urinary incontinence ^2,^ ^6^ | The complaint of involuntary leakage associated with urgency and also with exertion, effort, sneezing, or coughing
Situational urinary incontinence | The report of incontinence during sexual intercourse, or giggle incontinence.
Continuous urinary leakage | Complaint of continuous urinary leakage
Acute incontinence ^7^ | Sudden onset of symptoms related to an illness, treatment, or medication
Chronic incontinence | Persistent urinary incontinence includes disorders of storage (stress and urge), disorder of emptying (overflow), and functional and mixed incontinence.
Severity of incontinence | Incontinent episodes/unit time; pad changes/unit time; pad weight/unit time; number of micturitions/unit time; urinary pad test—measured loss; urodynamic-diagnosed detrusor overactivity; urodynamic stress incontinence
Sandvik's severity index ^8^ | Multiplied reported frequency (4 levels) by the amount of leakage (2 levels).
Slight incontinence | Leakage of drops a few times a month (~6g/24 hours, 95%CI 2–9)
Moderate incontinence | Daily leakage or drops (~17g/24 hours, 95%CI 13–22)
Severe incontinence | Leakage of large amount of urine at least once a week (~56g/24 hours, 95%CI 44–67)
Impact of incontinence | Actions patients have taken to ameliorate the incontinence including wearing pads, reducing activities, seeking medical treatment (visits to clinicians, prescriptions of medications, surgical procedures).
Impact of incontinence on quality of life | Measurement using a validated generic or condition-specific measure of quality of life developed to address issues related specifically to fecal incontinence or urinary incontinence
Remission of incontinence | Diminution of symptoms and signs of incontinence.
Contained Incontinence | Urine contained with pads or appliances
Dependent Continence | Dry with toileting assistance, behavioral treatment, and/pr medications
Independent Continence | Dry, not dependent on ongoing treatment
Symptoms of Incontinence ^2,^ ^6^ | The subjective indicator of incontinence or change in its severity as perceived by the patient, caregiver, or partner and may lead him/her to seek help from health care professionals.
Signs of Incontinence | Observed by the physician including simple means, to verify symptoms and quantify them.
Urodynamic observations | Observations made during urodynamic studies which have a number of possible underlying causes and do not represent a definitive diagnosis of a disease.
Measures of the frequency, severity and impact of urinary incontinence ^2^
Micturition time chart | Records of times of micturitions, day and night, for at least 24 hours.
Frequency volume chart (FVC) | Records of volumes voided as well as the time of each micturition, day and night, for at least 24 hours.
Bladder diary | Records of times of micturitions and voided volumes, incontinence episodes, pad usage, and other information such as fluid intake, the degree of urgency, and the degree of incontinence.
Daytime frequency | The number of voids recorded during waking hours and includes the last void before sleep and the first void after waking and rising in the morning.
24-hour frequency | The total number of daytime voids and episodes of nocturia during a specified 24-hour period
24-hour production | All urine produced during 24 hours
Maximum voided volume | The largest volume of urine voided during a single micturition and is determined either from the frequency/volume chart or bladder diary.
Pelvic floor muscle function | Measured during rectal examination by the tone at rest and the strength of a voluntary contraction, as strong, weak or absent. A pelvic muscle contraction may be assessed by visual inspection, by palpation, electromyography, or perineometry. Factors to be assessed include strength, duration, displacement, and repeatability
Pad testing | The amount of urine lost during incontinence episodes (a short provocative test to a 24-hour pad test)
Improvement in incontinence | Reduction frequency and severity of incontinence episodes. Reduction in restrictions of daily activities due to incontinence.
Progression of incontinence | Increase in frequency and severity of incontinence episodes. Increase in restrictions of daily activities due to incontinence. Failure of achieve continence. Failure to reduce frequency and severity of incontinent episodes.
Urodynamic Techniques ^2,^ ^9^ – ^11^
Conventional urodynamic studies | Urodynamic laboratory measurement of artificial bladder filling—filling the bladder, via a catheter, with a specified liquid at a specified rate.
Ambulatory urodynamic studies | A functional test of the lower urinary tract, utilizing natural filling (the bladder is filled by the production of urine rather than by an artificial medium), and reproducing the subject's every day activities
Intravesical pressure | The pressure within the bladder
Abdominal pressure | The pressure surrounding the bladder. In current practice it is estimated from rectal, vaginal or, less commonly, from extraperitoneal pressure or a bowel stoma. The simultaneous measurement of abdominal pressure is essential for the interpretation of the intravesical pressure trace.
Detrusor pressure | The component of intravesical pressure that is created by forces in the bladder wall (passive and active). It is estimated by subtracting abdominal pressure from intravesical pressure.
Filling cystometry | Urodynamic investigation of the filling phase of the micturition cycle. The method by which the pressure/volume relationship of the bladder is measured during bladder filling
Bladder function during filling. | The rate at which the bladder is filled.
Physiological filling rate | A filling rate less than the predicted maximum - predicted maximum body weight in kg divided by 4 expressed as ml/min
Nonphysiological filling rate | A filling rate greater than the predicted maximum filling rate -predicted maximum body weight in kg divided by 4 expressed as ml/min.
Bladder storage function | Bladder sensation, detrusor activity, bladder compliance, and bladder capacity.
Normal bladder sensation | Sensation judged by three defined points noted during filling cystometry and evaluated in relation to the bladder volume at that moment and in relation to the patient's symptomatic complaints.
First sensation of bladder filling | The feeling the patient has, during filling cystometry, when he/she first becomes aware of the bladder filling.
First desire to void | The feeling, during filling cystometry that would lead the patient to pass urine at the next convenient moment, but voiding can be delayed if necessary.
Strong desire to void | Persistent desire to void without the fear of leakage.
Increased bladder sensation | An early first sensation of bladder filling (or an early desire to void) and/or an early strong desire to void, which occurs at low bladder volume and which persists.
Reduced bladder sensation | Diminished sensation throughout bladder filling.
Absent bladder sensation | The absence of bladder sensation during filling cystometry.
Bladder pain | A self explanatory term and is an abnormal finding.
Urgency | A sudden compelling desire to void.
The vesical/urethral sensory threshold | The least current which consistently produces a sensation perceived by the subject during stimulation at the site under investigation.
Normal detrusor function | Bladder filling with little or no change in pressure. No involuntary phasic contractions occur despite provocation.
Detrusor overactivity | An urodynamic observation characterized by involuntary detrusor contractions during the filling phase which may be spontaneous or provoked.
Phasic detrusor overactivity | Defined by a characteristic wave form and may or may not lead to urinary incontinence
Terminal detrusor overactivity | A single, involuntary detrusor contraction, occurring at cystometric capacity, which cannot be suppressed and results in incontinence usually resulting in bladder emptying (voiding).
Detrusor overactivity incontinence | Incontinence due to an involuntary detrusor contraction.
Neurogenic detrusor overactivity | Detrusor overactivity caused by a relevant neurological condition.
Idiopathic detrusor overactivity | Detrusor overactivity with unknown cause.
Provocative maneuvers | Techniques used during urodynamics in an effort to provoke detrusor overactivity; for example, rapid filling, use of cooled or acid medium, postural changes and hand washing.
Bladder compliance during filling
Cystometry | Description of the relationship between change in bladder volume and change in detrusor pressure; calculated by dividing the volume change (ΔV) by the change in detrusor pressure (Δpdet) during that change in bladder volume (C=V. Δpdet). It is expressed in ml/cm H2O.
| Two standard points:
| 1 The detrusor pressure at the start of bladder filling and the corresponding bladder volume (usually zero); 2 The detrusor pressure (and corresponding bladder volume) at cystometric capacity or immediately before the start of any detrusor contraction that causes significant leakage (and therefore causes the bladder volume to decrease, affecting compliance calculation). Both points are measured excluding any detrusor contraction.
Bladder capacity during filling cystometry
Cystometric capacity | The bladder volume at the end of the filling cystometrogram, when “permission to void” is usually given. The end point should be specified, for example, if filling is stopped when the patient has a normal desire to void. The cystometric capacity is the volume voided together with any residual urine.
Maximum cystometric capacity | The volume at which the patient feels he/she can no longer delay micturition (has a strong desire to void).
Maximum anaesthetic bladder capacity | The volume to which the bladder can be filled under deep general or spinal anesthetic and should be qualified according to the type of anesthesia used and the speed, the length of time, and the pressure at which the bladder is filled.
Urethral function during filling cystometry | The urethral closure mechanism during storage
Normal urethral closure mechanism | A positive urethral closure pressure during bladder filling even in the presence of increased abdominal pressure, although it may be overcome by detrusor overactivity.
Incompetent urethral closure mechanism | Patho-physiologic condition which allows leakage of urine in the absence of a detrusor contraction.
Urethral relaxation incontinence | A leakage due to urethral relaxation in the absence of raised abdominal pressure or detrusor overactivity.
Urodynamic stress incontinence (genuine stress incontinence) | The involuntary leakage of urine during increased abdominal pressure, in the absence of a detrusor contraction
Assessment of urethral function during filling cystometry
Urethral pressure measurement | The fluid pressure needed to just open a closed urethra.
The urethral pressure profile | A graph indicating the intraluminal pressure along the length of the urethra
The urethral closure pressure profile | Given by the subtraction of intravesical pressure from urethral pressure
Maximum urethral pressure | The maximum pressure of the measured profile.
Maximum urethral closure pressure (MUCP) | The maximum difference between the urethral pressure and the intravesical pressure.
Functional profile length | The length of the urethra along which the urethral pressure exceeds intravesical pressure in women.
Pressure “transmission” ratio | The increment in urethral pressure on stress as a percentage of the simultaneously recorded increment in intravesical pressure
Abdominal leak point pressure | The intravesical pressure at which urine leakage occurs due to increased abdominal pressure in the absence of a detrusor contraction.
Detrusor leak point pressure | The lowest detrusor pressure at which urine leakage occurs in the absence of either a detrusor contraction or increased abdominal pressure.
Pressure Flow Studies | The method by which the relationship between pressure in the bladder and urine flow rate is measured during bladder emptying.
Urine flow | Continuous, that is without interruption, or as intermittent urine flow, when an individual states that the flow stops and starts during a single visit to the bathroom in order to void. The continuous flow curve is defined as a smooth arc-shaped curve or fluctuating when there are multiple peaks during a period of continuous urine flow
Flow rate | The volume of fluid expelled via the urethra per unit time expressed in ml/s
Voided volume | The total volume expelled via the urethra
Maximum flow rate | The maximum measured value of the flow rate after correction for artifacts
Voiding time | Total duration of micturition, i.e., includes interruptions. When voiding is completed without interruption, voiding time is equal to flow time
Flow time | The time over which measurable flow actually occurs.
Average flow rate | Voided volume divided by flow time. The average does not reflect flow interruptions or terminal dribble.
Time to maximum flow | The elapsed time from onset of flow to maximum flow.
Pressure measurements during pressure flow studies (PFS)
Premicturition pressure | The pressure recorded immediately before the initial isovolumetric contraction.
Opening pressure | The pressure recorded at the onset of urine flow.
Opening time | The elapsed time from initial rise in detrusor pressure to onset of flow.
Maximum pressure | The maximum value of the measured pressure
Pressure at maximum flow | The lowest pressure recorded at maximum measured flow rate.
Closing pressure | The pressure measured at the end of measured flow.
Minimum voiding pressure | The minimum pressure during measurable flow but is not necessarily equal to either the opening or closing pressures.
Flow delay | The time delay between a change in bladder pressure and the corresponding change in measured flow rate.
Detrusor function during voiding
Normal detrusor function | Allows bladder filling with little or no change in pressure. No involuntary phasic contractions occur despite provocation
Detrusor underactivity | A contraction of reduced strength and/or duration, resulting in prolonged bladder emptying and/or a failure to achieve complete bladder emptying within a normal time span.
Acontractile detrusor | No contractility can be detected during urodynamic studies.
Post void residual (PVR) | The volume of urine left in the bladder at the end of micturition
Urethral function during voiding
Normal urethra function | Urethra that opens and is continuously relaxed to allow the bladder to be emptied at a normal pressure.
Abnormal urethra function | Obstruction to urethral overactivity or the urethra cannot open due to anatomic abnormality, such as an enlarged prostate or a urethral stricture
Bladder outlet obstruction | Obstruction during voiding and is characterized by increased detrusor pressure and reduced urine flow rate diagnosed by studying the synchronous values of flow rate and detrusor pressure.
Dysfunctional voiding | An intermittent and/or fluctuating flow rate due to involuntary intermittent contractions of the periurethral striated muscle during voiding in neurologically normal individuals.
Detrusor sphincter dyssynergia | A detrusor contraction concurrent with an involuntary contraction of the urethral and/or periurethral striated muscle.
Non-relaxing urethral sphincter obstruction | Non-relaxing, obstructing urethra resulting in reduced urine flow in individuals with a neurological lesion

Long-term care—care over an extended period, usually for a chronic condition or disability, requiring periodic, intermittent, or continuous care

Conceptual definition of race—continental population groups of individuals whose putative ancestry is from native continental populations based on similarities in physical appearance

Conceptual definition of ethnicity—ethnic groups of people with a common cultural heritage that sets them apart from others in a variety of social relationships

Table 2 Operational definitions of patient race and ethnicity ^12^

Variable | Definition
Race
African Continental Ancestry Group | Individuals whose ancestral origins are in the continent of Africa.
Asian Continental Ancestry Group | Individuals whose ancestral origins are in the continent of Asia.
European Continental Ancestry Group | Individuals whose ancestral origins are in the continent of Europe
Ethnic Groups
African Americans | Persons living in the United States having origins in any of the black groups of Africa
Arabs | Members of a Semitic people inhabiting the Arabian peninsula or other countries of the Middle East and North Africa. The term may be used with reference to ancient, medieval, or modern ethnic or cultural groups
Asian Americans | Persons living in the United States having origins in any of the original peoples of the Far East, Southeast Asia, or the Indian subcontinent.
Hispanic Americans | Persons living in the United States of Mexican (Mexican Americans), Puerto Rican, Cuban, Central or South American, or other Spanish culture or origin. The concept does not include Brazilian Americans or Portuguese Americans.

Conceptual definitions of risk factors ^12^ —aspects of personal behavior or lifestyle, environmental exposure, or inborn or inherited characteristic, which, on the basis of epidemiologic evidence, is known to be associated with urinary and fecal incontinence considered important to prevent incontinence.

Prevalence of incontinence—probability of experiencing a symptom or having a disease within a defined population and at a defined time point. ^1,^ ^6^

Incidence—probability of developing incontinence under study during a defined time period, usually reported for one, two-, or five-year interval. ^1,^ ^6^

Relative risk estimation of the magnitude of an association between exposure and a condition, indicates the likelihood of having the condition in the exposed group relative to those who are not exposed. ^1,^ ^6^

Odds ratio is the odds for having a risk factor in persons with a condition divided by the odds among those without the condition ^1,^ ^6^ .

Table 3 Operational definitions of known risk factors of urinary and fecal incontinence

Variable | Definition
Age | Persons classified by age from birth to octogenarians and older Age categories: 19–44 years; 45–64 years, 65+ years; 80 and over
Elderly | Aged- person 65 through 79 years of age; 80 and over
Functional impairment (Frailty) ^13^ | Combination of three or more of five factors: unintentional weight loss (10 pounds or more in a year); general feeling of exhaustion; weakness (as measured by grip strength); slow walking speed; low levels of physical activity.
Prostate disorders ^3,^ ^4^ | Prostatic enlargement, urethral stricture, bladder neck contracture, or prostate cancer that may cause urethral obstruction
Pregnancy ^12^ | The status during which female mammals carry their developing young embryos, or fetuses in uteri before birth, beginning from fertilization to birth
Postpartum period | In females, 4 weeks after giving birth
Menopause | The last menstrual period. Permanent cessation of menses usually defined after 6 to 12 months of amenorrhea in a woman over 45 years of age.
Institutionalization | Caring for individuals in institutions and their adaptation to routines characteristic of the institutional environment, and/or their loss of adaptation to life outside the institution.
Dementia | An acquired organic mental disorder with loss of intellectual abilities of sufficient severity to interfere with social or occupational functioning. The dysfunction is multifaceted and involves memory, behavior, personality, judgment, attention, spatial relations, language, abstract thought, and other executive functions. The intellectual decline is usually progressive, and initially spares the level of consciousness.
Depression | Depressive states usually of moderate intensity in contrast with major depression present in neurotic and psychotic disorders
Depressive disorder | An affective disorder manifested by either a dysphoric mood or loss of interest or pleasure in usual activities. The mood disturbance is prominent and relatively persistent.
Depression, postpartum | Depression in postpartum women, usually within four weeks after giving birth. The degree of depression ranges from mild transient depression to neurotic or psychotic depressive disorders
Depressive disorder, major | Marked depression appearing in the involution period and characterized by hallucinations, delusions, paranoia, and agitation
Psychiatric disorders | Psychiatric illness or diseases manifested by breakdowns in the adaptational process expressed primarily as abnormalities of thought, feeling, and behavior producing either distress or impairment of function
Diabetes | A heterogeneous group of disorders characterized by hyperglycemia and glucose intolerance
Diabetes mellitus, Type 2 | A subclass of diabetes that is not Insulin-responsive or dependent (NIDDM). It is characterized initially by insulin resistance and hyperinsulinemia; and eventually by glucose intolerance; hyperglycemia and overt diabetes. Patients often exhibit obesity
Diabetes mellitus, Type 1 | A subtype of diabetes mellitus that is characterized by Insulin deficiency. It is manifested by the sudden onset of severe hyperglycemia, rapid progression to diabetic ketoacidosis, and death unless treated with insulin.
Obesity | A status with body weight that is grossly above the acceptable or desirable weight, usually due to accumulation of excess fats in the body. The standards may vary with age, sex, genetic or cultural background. In the body mass index, a BMI greater than 30.0 kg/m2 is considered obese, and a BMI greater than 40.0 kg/m2 is considered morbidly obese
Diet | Regular course of eating and drinking adopted by a person measured by a nutrient intake over a specific period of time
Irritable bowel syndrome | A disorder with chronic or recurrent colonic symptoms. This condition is characterized by chronic or recurrent abdominal pain, bloating, mucus in feces, and an erratic disturbance of defecation
Diarrhea | An increased liquidity or decreased consistency of feces, such as running stool. Fecal consistency is partially related to the ratio of water-holding capacity of insoluble solids to total water, rather than only the amount of water present. Diarrhea is not hyperdefecation or increased fecal weight
Constipation ^14^ | Presence of at least two symptoms, which must be present at least 25% of the time. Symptoms include: fewer than 3 bowel movements per week, hard or lumpy stools, straining with defecation, a sensation of incomplete evacuation, a sensation of anorectal obstruction, and the use of manual maneuvers to assist defecation.
| Chronicity: 12 weeks in the previous year, which do not need to be consecutive.
| 3 subtypes: ^14^ colonic inertia (delayed motility), outlet obstruction, and functional constipation.
Inflammatory Bowel Diseases | Chronic, nonspecific inflammation of the gastrointestinal tract including Crohn disease and ulcerative colitis
Irritable Bowel Syndrome | A disorder with chronic or recurrent colonic symptoms without a clear-cut etiology characterized by chronic or recurrent abdominal pain, bloating, mucus in feces, and an erratic disturbance of defecation
Fecal impaction | Formation of a firm impassable mass of stool in the rectum or distal colon
Cardiovascular diseases | Pathological conditions involving the cardiovascular system including the heart; blood vessels; or pericardium: arrhythmia; congestive heart failure; coronary disease; myocardial infarction; hypertension
Smoking | Inhaling and exhaling the smoke of tobacco or something similar to tobacco
Smoking related respiratory tract diseases | Lung neoplasm
| Chronic obstructive pulmonary disease—a disease of chronic diffuse irreversible airflow obstruction
| Pneumonia—Inflammation of the lungs
| Asthma—A form of bronchial disorder associated with airway obstruction, marked by recurrent attacks of paroxysmal dyspnea, with wheezing due to spasmodic contraction of the bronchi.
Gastrointestinal procedures | Proctocolectomy, Restorative—A surgical procedure involving the excision of the colon and rectum and the formation of an illeoanal reservoir
Major abdominal/pelvic surgery | Anterior resection; abdominal aortic aneurism surgery
Gynecologic procedures | Surgery performed on the female genitalia.
| Colposcopy—The examination, therapy or surgery of the cervix and vagina by means of a specially designed endoscope introduced vaginally
| Culdoscopy—Endoscopic examination, therapy, or surgery of the female pelvic viscera by means of an endoscope introduced into the pelvic cavity through the posterior vaginal fornix.
| Hysteroscopy—Endoscopic examination, therapy, or surgery of the interior of the uterus
| Gynecological surgery for pelvic organ prolapse repair, pelvic organ prolapse
Urologic surgical procedures | Surgery performed on the urinary tract or its parts in the male or female
| Cystectomy—Used for excision of the urinary bladder
| Cystoscopy—Endoscopic examination, therapy, or surgery of the urinary bladder
| Ureteroscopy—Endoscopic examination, therapy, or surgery of the ureter.
| Urinary diversion—Temporary or permanent diversion of the flow of urine through the ureter away from the urinary bladder in the presence of a bladder disease or after cystectomy
| Prostatectomy—Complete or partial surgical removal of the prostate. Three primary approaches are commonly employed: suprapubic—removal through an incision above the pubis and through the urinary bladder; retropubic—as for suprapubic but without entering the urinary bladder; and transurethral
| Ultrasound, high-intensity focused, transrectal—Tissue ablation of the prostate performed by ultrasound from a transducer placed in the rectum
Stroke | A sudden, nonconvulsive loss of neurologic function due to an ischemic or hemorrhagic intracranial vascular event classified by anatomic location in the brain, vascular distribution, etiology, age of the affected individual, and hemorrhagic vs. nonhemorrhagic nature
Spinal cord diseases | Pathologic conditions which feature spinal cord damage or dysfunction, including disorders involving the meninges and perimeningeal spaces surrounding the spinal cord. Traumatic injuries, vascular diseases, infections, and inflammatory/autoimmune processes may affect the spinal cord.
Hip fractures | Fractures of the femur head; the femur neck; the trochanters; or the inter- or subtrochanteric region
Degenerative joint diseases | Diseases of the bones and cartilage viewed collectively.
Osteoarthritis | A progressive, degenerative joint disease, the most common form of arthritis, especially in older persons
Parkinson's disease | A progressive, degenerative neurologic disease characterized by a tremor that is maximal at rest, retropulsion, rigidity, stooped posture, slowness of voluntary movements, and a mask like facial expression.
Multiple sclerosis | An autoimmune disorder mainly affecting young adults and characterized by destruction of myelin in the central nervous system. Pathologic findings include multiple sharply demarcated areas of demyelination throughout the white matter of the central nervous system. Clinical manifestations include visual loss, extra-ocular movement disorders, paresthesias, loss of sensation, weakness, dysarthria, spasticity, ataxia, and bladder dysfunction
Rectal diseases and surgeries | Hemorroidectomy -surgical removal of hemorrhoids; bowel resection; anal and recto-vaginal fistula; rectal prolapse; acute sphincter trauma and sphincter repair
Obstetrical and other injuries to the pelvic floor | Parity—the number of offspring a female has borne
| Delivery, Obstetric—delivery of the fetus and placenta under the care of an obstetrician or a health worker including vaginal, forceps delivery; vacuum extraction; episiotomy; and cesarean.
| Fetal characteristics: increased fetal weight and head circumference
Family History | History of incontinence in parents and first degree siblings
History of childhood nocturnal enuresis | History of childhood involuntary discharge of urine during sleep at night after expected age of completed development of urinary control
Demographics:
Education | Educational attainment or level of education of individuals
Socioeconomic factors | Social and economic factors that characterize the individual or group within the social structure
Marital status | Person's status with respect to marriage, divorce, widowhood, singleness.
Physical activity | The physical activity as a behavioral phenomenon characterized by frequency and intensity of motor activity per unit of time (day, week).
Sexual abuse | Violation of established legal or moral codes in respect to sexual behavior. A condition in which there is a derivation of pleasure from inflicting pain, discomfort, or humiliation on another person or persons.
Torture | The intentional infliction of physical or mental suffering upon an individual.
Sodomy | Anal sexual intercourse
Alcohol use | Behaviors associated with the ingesting of alcoholic beverages, including social drinking
Nutritional deficits, malnutrition, fiber-free tube-feeding formulas | An imbalanced nutritional status resulting from insufficient intake of nutrients to meet normal physiological requirement. Nutritional support given via the alimentary canal or any route connected to the gastrointestinal system (i.e., the enteral route). This includes oral feeding, sip feeding, and tube feeding using nasogastric, gastrostomy, and jejunostomy tubes
Mobility status | Bedbound, wheelchair bound, assistive device; physical restraints
Sleep disturbances | Conditions characterized by disturbances of usual sleep patterns or behaviors: dyssomnias (i.e., disorders characterized by insomnia or hypersomnia), parasomnias (abnormal sleep behaviors), and sleep disorders secondary to medical or psychiatric disorders

Conceptual definition of clinical interventions to reduce the risk of fecal and urinary incontinence—epidemiologic investigations designed to test a hypothesized cause-effect relation between intervention and incidence (progression) of fecal and urinary incontinence in the study population

Primary prevention—specific practices for the prevention of incontinence in susceptible individuals or populations; aims to remove the causes of the disease

Secondary prevention ^1,^ ^6^ — intervention for existing symptoms of incontinence to prevent disease progression

Table 4 Operational definitions of clinical interventions for the primary and secondary prevention of incontinence

Variable | Definition
Health education | Education that increases the awareness and favorably influences the attitudes and knowledge relating to the early detection and prevention of fecal and urinary incontinence
Behavioral therapy | The application of behavioral changes to detect and manage incontinence including: education about urinary and fecal tract structure and function; development of individualized diaries of daily dietary, physical activities, urinary and fecal habits; pelvic floor muscle exercises; voiding schedules: prompted, timed, habit retraining, patterned urge response toileting
Biofeedback | Process by which a person uses biofeedback information to gain voluntary control over pelvic floor muscle function, urination and defecation processes
Pelvic floor muscle training for urinary incontinence | A systematic program of pelvic floor muscle exercises (Kegel exercises) designed to improve the strength and coordination of the pelvic floor muscles in order to improve urinary sphincter function and to control urgency
Pelvic floor muscle training for fecal incontinence | Training technique to become aware of the presence of fecal material in the rectum and relearning skills necessary for coordinating contractions of external anal sphincter and improving the force of muscle contraction.
Vaginal cones | Insertion of vaginal cone (weighted device) into the vagina and contraction of the pelvic floor muscles in an effort to hold the device in place.
Electrical stimulation | Application of electric current in treatment without the generation of perceptible heat.
| Using low-voltage electric current to stimulate the correct group of muscles delivered using an anal or vaginal probe
Sacral neuromodulation | Placement of a “bladder pacemaker” for continuous stimulation to the sacral nerve that controls the urinary sphincter
| Placement of a “pacemaker” for continuous stimulation of the sacral nerves to control fecal incontinence
| Percutaneous tibial neuromodulation—Placement of a fine needle into the skin above the ankles for intermittent stimulation of the post tibial nerve
Urethral “plugs” and patches | Insertion of plastic shapes into the urethra to stop the flow of urine or placed externally at the urinary meatus to prevent urine leakage; Used for female stress urinary incontinence
Pessaries | A plastic or silicone device which is inserted into the vagina to provide support to the uterus, vagina, bladder, or rectum when there is pelvic organ prolapse. Special pessaries with knobs are available for use in treatment of urinary incontinence.
Sanitary shield | Sanitary products for a single use in incontinent patients
Penile compression devices | A special clamp that is placed around the penis to prevent urinary leakage.
Intermittent catheterization | Drainage or aspiration of the bladder or a urinary reservoir with subsequent removal of the catheter.
| Intermittent self-catheterization is performed by the patient himself/herself
| Intermittent catheterization is performed by an attendant (e.g., doctor, nurse or relative)
| Clean intermittent catheterization: use of a clean technique. This implies ordinary washing techniques and use of disposable or cleansed reusable catheters.
| Aseptic intermittent catheterization: use of a sterile technique. This implies genital disinfection and the use of sterile catheters and instruments/gloves.
Indwelling catheterization | Indwelling catheter remains in the bladder, urinary reservoir, or urinary conduit for a period of time longer than one emptying.
| Clamps and compression rings in males are placed over the penis to squeeze the urethra shut
Bladder reflex triggering | Various maneuvers performed by the patient or the therapist in order to elicit reflex detrusor contraction by exteroceptive stimuli including suprapubic tapping, thigh scratching, and anal/rectal manipulation.
Weight loss | Intentional decrease in existing body weight as a results of reduced calorie intake and/or increased physical activity
Smoking cessation | Discontinuation of the habit of smoking, the inhaling and exhaling of tobacco smoke
Diet therapy | Adjusting the quantity and quality of food intake to improve health status of an individual (alcohol, fluid, and caffeine intake)
Magnetic stimulation | Stimulation with a brief magnetic field on the pelvic floor muscles and sacral roots without insertion of an annals or vaginal probe
Elective Caesarian delivery | Extraction of the fetus by means of abdominal hysterotomy
Direct neuromodulation of the sacral spinal cord | Placement of quadripolar electrode into S3 foramen for stimulation of S3 nerve in order to normalize vesico urethral function
Urethropexy | Surgical suspension of the urethra from the posterior surface of the pubic symphysis in order to correct urinary stress incontinence
Laparoscopic and open Burch retropubic urethropexies | Extra/transperitoneal laparoscopic/retropubic urethropexies using non absorbable sutures or prolene meshes fixed with tackers or staplers
Abdominal sacrocolpopexy | Support of the vaginal vault by affixing it to the periosteum of the sacrum following a hysterectomy
| Traditional Burch urethropexy included the basic principles of the Tanagho modification: (1) minimal dissection within 2cm of the urethrovesical junction and urethra, (2) placement of sutures through full thickness of shiny white paravaginal fascia, (3) use of two sutures on each side, one opposite to the urethrovesical junction and another at the level of the midurethra, (4) removal of adipose tissue lateral to the sutures to stimulate fibrosis, and (5) facilitating typing of sutures to the Cooper ligament with intravaginal fingers elevating the anterior vaginal wall. Modified Burch colposuspension includes the suspension of anterior vaginal wall at the level of the bladder neck with permanent sutures connected to the iliopectineal ligament
Urethral bulking procedures: | Artificially inflating the submucosal tissues of the bladder neck
Transurethral or periurethral injection techniques for females and transurethral or antegrade injection for males | Urethral bulking agents approved by the FDA include collagen (Contigen), autologous fat, and carbon bead technology (Durasphere).
| Autologous fat from the lower abdomen injected around the urethra. Glutaraldehyde, cross-linked collagen-extracted and purified bovine collagen. Durasphere - pyrolytic carbon-coated beads suspended in a water-based gel. Synthetic calcium hydroxylapatite, cross-linked hyaluronic acid (HA), and ethylene vinyl alcohol copolymer suspended in dimethyl sulfoxide are under investigation.
Anterior colporrhaphy (anterior repair) | An operation of placating and suturing the anterior wall of the vagina to provide support to the anterior wall of the vagina and the bladder.
Posterior colporrhaphy (posterior repair) | An operation of placating and suturing of the posterior wall of the vagina to provide support to the rectum.
Artificial bowel sphincter | A surgical procedure that inserts an inflatable artificial sphincter in cases of bowel (fecal) incontinence caused by a sphincter dysfunction or injury.
| Devices implanted under the skin to mimic the natural function of the anal sphincter include an inflatable cuff, placed in the anus, a balloon reservoir, placed in the pubic area, and a pump, placed in the pubic area, connecting the cuff and balloon
Overlapping sphincteroplasty | A surgical technique designed to restore integrity and function to anal sphincter:
| Incision and removal of episiotomy scar tissue from the sphincter muscles; mobilization of external anal sphincter muscle; the stitching of muscle to itself
Dynamic graciloplasty | Transposition of the gracilis muscle to the anus with the implantation of stimulating electrodes
Hormone replacement therapy | Therapeutic use of hormones to alleviate the effects of hormone deficiency in menopausal females
Topical estrogen therapy | Topical vaginal administration of estrogenes

Table 5 Clinical interventions by type of incontinence

Urinary Incontinence | Fecal Incontinence
Prolapse surgery | Prolapse surgery
Estrogens: Topical; oral | Dietary fiber supplements, diet high in fiber foods, or fiber supplemented tube feeding formula
Scheduled voiding regimens, e.g., timed voiding, prompted voiding, patterned urge response toileting, habit training, bladder training | Yogurt, other lactobacillus preparations, or and other probiotics, fructooligosaccharides
Pelvic floor muscle training | Diet modifications: avoiding caffeine, sorbitol containing artificial sweeteners
Vaginal cones | Overlapping sphincteroplasty
Biofeedback | Dynamic graciloplasty
Electrical stimulation | Biofeedback
Urethral “plugs,” patches, and urethral pessaries | Electrical stimulation
Penile compression devices | Antimotility or antidiarrheal medications
Bladder reflex triggering | Artificial bowel sphincter
Detrol (tolterodine tartrate) | Anal plug
Ditropan, oxytrol (oxybutynin chloride) | Overlapping sphincteroplasty
Sanctura (trospium chloride) | Pelvic floor muscle or Kegel exercises
Enablex (darifenacin) | Urgency suppression, relaxation
Vesicare (solifenacin succinate) | Bowel training techniques: toileting, prompting, scheduled toileting upon awakening or after meals, digital stimulation, abdominal massage
Magnetic stimulation | Rectal evacuation or irrigation using small enema, suppository or laxative
Direct neuromodulation of the sacral spinal nerves | Direct neuromodulation of the sacral spinal nerves
Percutaneous nerve stimulation
Urethropexy
Laparoscopic and open Burch retropubic urethropexies
Abdominal sacrocolpopexy
Anterior colporrhaphy (anterior repair)
Posterior colporrhaphy (posterior repair)
Artificial sling
Botulinum toxin injections for detrusor-sphincter dyssyndergia or detrusor hyperreflexia)
Bulking injections

Commonly used medications that may affect urinary and fecal continence

Type of Medication | Examples | Potential Effects on Continence
Sedatives/hypnotics | Long-acting benzodiazepines (e.g., diazepam, flurazepam) | Sedation, delirium, immobility
Alcohol | | Polyuria, frequency, urgency, sedation, delirium, immobility
Anticholinergics | Dicyclomine, disopyramide, sedating antihistamines | Urinary retention, overflow incontinence, delirium, impaction
Antipsychotics | Thioridazine, haloperidol | Anticholinergic actions, sedation, rigidity, immobility
Tricyclic antidepressants | Amitriptyline, desipramine | Anticholinergic actions, sedation
Selective serotonin reuptake inhibitors Serotonin norepinephrine reuptake inhibitors | Duloxetine fluoxetine, citalopram, paroxetine, sertraline, fluvoxamine, and venlafaxine
Antiparkinsonians | Trihexyphenidyl, benztropine mesylate (not L-dopa/selegiline) | Anticholinergic actions, sedation
Narcotic analgesics | Opiates | Urinary retention, fecal impaction, sedation, delirium
α-Adrenergic antagonists | Prazosin, terazosin, doxazosin | Urethral relaxation may precipitate stress incontinence in women
α-Adrenergic agonists | Nasal decongestants | Urinary retention in men
Calcium channel blockers | All dihydropyridines | Urinary retention; nocturnal diuresis due to fluid retention
Potent diuretics | Furosemide, bumetanide | Polyuria, frequency, urgency
Angiotensin-converting enzyme inhibitors | Furosemide, bumetanide | Drug-induced cough can precipitate stress incontinence in women and in some men with prior prostatectomy
Thiazolidinediones | Rosiglitazone | Nocturnal diuresis due to fluid retention
Cyclooxygenase 2 selective NSAIDs | Rofecoxib, celecoxib | Nocturnal diuresis due to fluid retention
Vincristine | | Urinary retention

## Algorithm to Define Eligibility of Studies

### Research Question

1. What are the prevalence and incidence of fecal and urinary incontinence in the community and long-term care settings? By:

- Race
- Ethnicity
- Gender
- Age

What is the range of estimates?

What factors account for the variance?

- Nature of the sample
- Definition of incontinence
- Manner of ascertainment

### Verification/Selection of Study Eligibility

Criteria 1 - Confirm eligibility of target population
Eligible descriptors:
Adults in the community | Yes | No | Combined
Adults in long-term care settings | Yes | No | Combined
If NO - exclude
Criteria 2 - Confirm eligibility of the outcomes
Eligible descriptors:
Prevalence of urinary/fecal incontinence | Yes | No | Combined
Incidence of urinary/fecal incontinence | Yes | No | Combined
If NO - exclude
Criteria 3. Confirm eligible level of evidence
Eligible descriptors:
Large population based cross sectional analyses | | | Yes
Large population based cohort studies | | | Yes
Large cross sectional analyses in long-term care settings | | | Yes
Large cohort studies in long-term care settings | | | Yes
Case-series with more than 100 subjects | | | Yes
If NO for all descriptors - exclude

2. What are the independent contributions of risk factors for fecal and urinary incontinence, including:

- Age
- Frailty
- Prostate disorders
- Pregnancy and postpartum state
- Menopause
- Institutionalization
- Neurological impairment
- Dementia
- Psychiatric disorders, specifically depression
- Diabetes
- Obesity
- Chronic GI conditions such as IBS, diarrhea, constipation, and IBD
- Cardiovascular and pulmonary conditions, specifically smokers
- Gastrointestinal, gynecologic, and urological procedures
- Neurological disorders, such as stroke and spinal cord problems

### Verification/Selection of Study Eligibility

Criteria 1 - Confirm eligibility of target population
Eligible descriptors:
Adults in the community
Adults in long-term care settings | Yes | No | Combined
If NO - exclude
Criteria 2 - Confirm eligibility of the outcomes
Eligible descriptors:
Prevalence of urinary/fecal incontinence | Yes | No | Combined
Incidence of urinary/fecal incontinence | Yes | No | Combined
If NO - exclude
Criteria 3 - Confirm eligibility of risk factors
Eligible descriptors are listed in the tables with definitions (Table 2)
If NO - exclude
Criteria 4 - Confirm eligible level of evidence
Eligible descriptors:
Large population based cross sectional analyses | | | Yes
Large population based cohort studies | | | Yes
Large cross sectional analyses in long-term care settings | | | Yes
Large cohort studies in long-term care settings | | | Yes
Case-series with more than 100 subjects | | | Yes
Case-control studies with randomly selected controls | | | Yes
If NO for all descriptors - exclude

3. What is the evidence to support specific clinical interventions to reduce the risk of fecal and urinary incontinence?

### Verification/Selection of Study Eligibility

Criteria 1 - Confirm eligibility of target population
Eligible descriptors:
Adults in the community
Adults in long-term care settings | Yes | No | Combined
If NO - exclude
Criteria 2 - Confirm eligibility of the outcomes
Eligible descriptors:
Prevalence of urinary/fecal incontinence | Yes | No | Combined
Incidence of urinary/fecal incontinence | Yes | No | Combined
Progression of urinary/fecal incontinence | Yes | No | Combined
If NO - exclude
Criteria 3 - Confirm eligibility of interventions
Eligible descriptors are listed in tables with definitions (Table 4–5)
If NO - exclude
Criteria 4 - Confirm eligible level of evidence
Eligible descriptors:
For the studies that examined urinary incontinence
Randomized controlled clinical trials | | Yes | No
If NO - exclude
For the studies that examined the effects of drug treatment on progression of incontinence:
Length of follow up 12 months or more | | Yes | No
If NO - exclude
For the studies that examined fecal and combined incontinence
Randomized controlled clinical trials | | Yes | No
Multi center not randomized clinical trials | | Yes | No
If NO - exclude

4. What are the strategies to improve the identification of persons at risk and patients who have fecal and urinary incontinence?

### Verification/Selection of Study Eligibility

Criteria 1 - Confirm eligibility of target population
Eligible descriptors:
Adults in the community
Adults in long-term care settings | Yes | No | Combined
If NO - exclude
Criteria 2 - Confirm eligibility of diagnostic strategies.
Eligible descriptors are listed in tables with definitions (Table 1) and in the Conceptual model 2.
If NO - exclude
Criteria 3 - Confirm eligibility of outcomes.
Eligible descriptors:
Diagnosis of urinary and fecal incontinence | Yes | No | Combined
Cost-effectiveness of diagnostic strategies | Yes | No | Combined
If NO - exclude
Criteria 4 - Confirm eligibility of the outcomes assessment:
Eligible descriptors:
True positive | | Yes | No
True negative | | Yes | No
False positive | | Yes | No
False negative | | Yes | No
Sensitivity | | Yes | No
Specificity | | Yes | No
Positive predictive likelihood of the test | | Yes | No
Validity of the scale | | Yes | No
Validity of the questionnaire | | Yes | No
Reliability of the scale | | Yes | No
Reliability of the questionnaire | | Yes | No
For the studies that examined urinary incontinence
Inter-observer variability | | Yes | No
If No for all descriptors - exclude
Criteria 5 - Confirm the eligible level of evidence:
Eligible descriptors:
Randomized controlled clinical trials | | Yes | No
Multicenter controlled clinical trials | | Yes | No
Large (>100 subjects) observational studies | | Yes | No
Case-control studies with >10 cases | | Yes | No
If No for all descriptors - exclude

[underlined: International classification of diseases, diagnostic codes of incontinence]: ^15^

625.6 Stress incontinence, female

787.6 Incontinence of feces

Encopresis NOS

Incontinence of sphincter ani

788.32 Stress incontinence, male

788.31 Urge incontinence

788.38 Overflow incontinence

788.39 Other urinary incontinence

788.34 Incontinence without sensory awareness

788.33 Mixed incontinence (female) (male)

596 Other disorders of bladder

788.30 Urinary incontinence, unspecified

788.63 Urgency of urination

788.3 Urinary incontinence

599.6 Urinary obstruction

Use additional code to identify urinary incontinence (625.6, 788.30–788.39)

598 Urethral stricture Includes: pinhole meatus; stricture of urinary meatus

Use additional code to identify urinary incontinence (625.6, 788.30–788.39)

596.51 Hypertonicity of bladder

Hyperactivity

Overactive bladder

344.61 With neurogenic bladder

Acontractile bladder

Autonomic hyperreflexia of bladder

Cord bladder

Detrusor hyperreflexia

788.43 Nocturia

788.41 Urinary frequency

Frequency of micturition

[underlined: Definitions of the studies' design characteristics to estimate the level of evidence].

Level of evidence as defined by the U.S. Preventive Services Task Force ^16^

Level I: Evidence obtained from at least one properly designed randomized controlled trial.

Level II-1: Evidence obtained from well-designed controlled trials without randomization.

Level II-2: Evidence obtained from well-designed cohort or case-control analytic studies, preferably from more than one center or research group.

Level II-3: Evidence obtained from multiple time series with or without the intervention. Dramatic results in uncontrolled trials.

Level III: Opinions of respected authorities, based on clinical experience, descriptive studies, or reports of expert committees.

[underlined: Independent intervention variables for the question 3 extracted from the studies]:

Type of intervention as a categorical variable: behavioral interventions, drug therapy, device therapy, surgery.

Type of intervention as a categorical variable using author's definitions.

Dose of the drug as a continuous variable.

[underlined: Dependent incontinence variables for question 3 extracted from the studies:]

Type of incontinence as a categorical variable: Urinary, Anal, Combined.

Urinary incontinence as stress, urge, mixed, total.

Anal incontinence as flatus, fecal, combined.

Incontinence outcomes as a categorical variable using author's definitions.

Number of cases with outcomes in the active and the control groups as a continuous variable.

Rates of outcomes (%) in the active and control groups as a continuous variable.

We applied intention-to treat principle and calculated the number of cases in the active and control groups among randomized when the authors reported the rates of outcomes among analyzed.

Outcomes level in the active and control groups as a continuous variable. We extracted means and standard deviations of outcomes from the articles. We calculated standard deviations when the authors reported standard errors:

Standard deviation = Standard Error * Square root of the sample size in the group.

We extracted medians when the authors did not reported means assuming normal distribution of the outcome.

Relative risk of the outcome in the active group compared to the control group.

Regression coefficient with standard error of association between intervention and outcome.

[underlined: Tested sources of heterogeneity]: ^17^

Clinical settings as a categorical variable: Community, nursing homes.

Sample size as a continuous variable equals the number of randomized subjects.

Proportion of females in the sample as a continuous variable (%)

Length of followup months as a continuous variable

Loss o followup as a continuous variable (%)

Masking of the treatment status as a categorical variable: open label, single blind, double blind

Adequacy of randomization and allocation concealment as a categorical variable: not reported, adequate, not adequate.

Intention to treat principle as categorical variable: Yes, no, not stated when all randomized subjects were analyzed but the authors did not plan Intention to treat principle in the study design.

We tested the possible sources of heterogeneity as interaction variables which could modify the effect of clinical interventions on incontinence outcomes and conducted sensitivity analysis within each category of effect modifiers.

[underlined: Analytical framework for pooled analysis of prevalence of incontinence in adults:]

Prevalence was calculated as number of subjects with incontinence among total number of patients in the study, standard error and confidence interval for population prevalence were calculated with Wilson estimate as follows: ^18^

95% level C confidence interval ρ±1.96*SEρ

Where p - prevalence, n- sample size. We calculated logarithm of prevalence for pooling analysis.

Hypotheses tested in pooled analysis ^19^

1 The urinary incontinence outcome is associated with an active treatment as a categorical variable compared to the control interventions. Random effects model was used to incorporate differences between studies.
2 The effect size of an active treatment can be modified by the proportion of males and females in the sample (when applicable).

We grouped pelvic floor muscle training programs into one category in the text and for a pooled analysis providing the details about different regimes of exercise in the tables.

We grouped different definitions of continence and improvement in incontinence to have an overall estimation of the interventions.

[underlined: Algorithms of meta-analysis] ^19^

Pooled estimate as a weighted average:

Weights are inverse of variance (standard error):

Standard error of pooled estimate:

Heterogeneity (between-study variability) measured by:

Assumptions for random effects model: true effect sizes qi have a normal distribution with mean q and variance t2; t2 is the between-study variance

Between study variance:

Where:

wi are the weights from the fixed effect inverse-variance method

Q is the heterogeneity test statistic from before (either from inverse-variance method or Mantel-Haenszel method)

k is the number of studies, and

t2 is set to zero if Q<k-1

Random effect pooled estimate is weighted average:

Weights used for the pooled estimate are similar to the inverse-variance, but now incorporate a component for between-study variation:

Standard error of pooled estimate

Meta regression with random effects was obtained using aggregate level data.

Additive component of variance tau2 was estimated:

y[i] = a + B*x[i] + u[i] + e[i],

where u[i] is a normal error (standard deviations that may vary across units), e[i] is a normal error with variance tau2 to be estimated, assumed equal across units.

t-distribution was used calculating p-values and confidence intervals ^17,^ ^20^

Attributable risk was calculated as the outcome events rate in patients exposed to different clinical interventions ^21^ – ^23^

Attributable risk of the outcome = rate of events in patients in the control group × (relative risk -1)

Number needed to treat to prevent one event of incontinence was calculated as reciprocal to absolute risk differences in rates of outcomes events in the active and control groups: ^22,^ ^24^

1/(control group event rate - treatment group event rate).

The number of avoided or excess events (respectively) per 1000 population is the difference between the two event rates multiplied by 1000:

(control group event rate - treatment group event rate)*1000

We calculated diagnostic values of different tests to diagnose incontinence:

Sensitivity=TP/(TP+FN)

Specificity=TN/(FP+TN)

Prevalence=(TP+FN)/(TP+FN+FP+TN)

Predictive value positive=TP/(TP+FP)

Positive predictive likelihood ratio:

[underlined: probability of an individual with the condition having a positive test]

LR+ = probability of an individual without the condition having a positive test

LR+ = [underlined: sensitivity]

1-specificity

Number needed to screen to identify one undiagnosed incontinence case = [(prevalence of undiagnosed incontinence)(sensitivity of the diagnostic method)]^-1^

Number of diagnostic tests to identify one undiagnosed incontinence case = 2 + number needed to screen (1 - prevalence of undiagnosed incontinence)(1 - specificity of the diagnostic test). ^25^

#### References for Analytical Framework

1 Abrams P, Cardozo L, Khoury S, et al. Incontinence. 3rd International Consultation on Incontinence. Plymouth: Health Publications; 2005.
2 Abrams P, Cardozo L, Fall M, et al. The standardisation of terminology in lower urinary tract function: report from the standardisation sub-committee of the International Continence Society. Urology. Jan. 2003;61(1):37-49. [pmid: 12559262].
3 Harrison TR, Braunwald E, NetLibrary Inc. Harrison's manual of medicine. McGraw-Hill Medical Pub. Division [Bibliographic record display; cover art; table of contents]. Available at: http://www.netLibrary.com/urlapi.asp?action=summary&v=1&bookid=71257 An electronic book accessible through the World Wide Web; click for information; http://firstsearch.oclc.org/WebZ/DCARead?standardNoType=1&standardNo=0071386793:srcdbname=worldcat:fromExternal=true&sessionid=0; http://firstsearch.oclc.org/WebZ/DECRead?standardNoType=1&standardNo=0071386793&sessionid=0&srcdbname=worldcat&key=9f445a411be7321b287f56545882bccdc6c69f97e9caead6ca1a155f6f99a63e&ectype=TOC; http://www.netLibrary.com/urlapi.asp?msg=iGwmKofsjNse7T654jizTngP2Cm82xVujo/AovWIOpcmiSuUkwCk1w18oiRSK4gcFXO/q4+KCm9A?kg8VEMAOFCBzc2G3/K7L9kRycyEvM1CEswyVBu8QiyZwaWQ9MTIzJmV0PTNk
4 Kasper DL, Harrison TR, NetLibrary Inc. Harrison's principles of internal medicine. McGraw-Hill Medical Pub. Division [Bibliographic record display]. Available at: http://www.netLibrary.com/urlapi.asp?action=summary&v=1&bookid=149871 An electronic book accessible through the World Wide Web; click for information; http://www.netLibrary.com/urlapi.asp?msg=iGwmKofsjNse7T654jizTngP2Cm82xVuelvum762Mna+xOR+sfqPcrGXnVx1MhztuL+vMLr8hIj2?wsPEqz3ptQ3GVJKsS5mv1mtfFGEET1yrO0ZeNrR13yZwaWQ9MTIzJmV0PTNk
5 Managing acute and chronic urinary incontinence. AHCPR Urinary Incontinence in Adults Guideline Update Panel. Am Fam Physician 1996 Oct; 54(5):1661–72.
6 Abrams P, Cardozo L, Khoury S, et al. Incontinence. Proceedings from the 3rd International Consultation on Incontinence. Paris, France: Health Publications, Ltd.; 2005.
7 Beers MH, Jones TV, Berkwits M, et al. The Merck manual of geriatrics. Merck Research Laboratories [Text electronic book; Full-text online]. Available at: http://library.umassmed.edu/ebooks/ebooksredirect.cfm?ID=164
8 Sandvik H, Hunskaar S, Seim A, et al. Validation of a severity index in female urinary incontinence and its implementation in an epidemiological survey. J Epidemiol Community Health. Dec. 1993;47(6):497-9. [pmid: 8120507]. [pmcid: 1059866].
9 Messelink B, Benson T, Berghmans B, et al. Standardization of terminology of pelvic floor muscle function and dysfunction: report from the pelvic floor clinical assessment group of the International Continence Society. Neurourol Urodyn. 2005;24(4):374-80. [pmid: 15977259].
10 Martin JL, Williams KS, Sutton AJ, et al. Systematic review and meta-analysis of methods of diagnostic assessment for urinary incontinence. Neurourol Urodyn. 2006;25(7):674-83. discussion 84. [pmid: 17016795].
11 Martin JL, Williams KS, Abrams KR, et al. Systematic review and evaluation of methods of assessing urinary incontinence. Health Technol Assess 2006 Feb; 10(6):1–132, iii–iv.
12 National Library of Medicine (U.S.), National Center for Biotechnology Information (U.S.), National Institutes of Health (U.S.). PubMed central: an archive of life science journals. NCBI U.S. National Library of Medicine NIH Dept. of Health and Human Services [Digital archive searchable database]. Available at: http://www.pubmedcentral.nih.gov/
13 Fried LP, Tangen CM, Walston J, et al. Frailty in older adults: evidence for a phenotype. J Gerontol A Biol Sci Med Sci. Mar. 2001;56(3):M146-56. [pmid: 11253156].
14 Thompson WG, Longstreth GF, Drossman DA, et al. Functional bowel disorders and functional abdominal pain. Gut. Sep. 1999;45(Suppl 2):II43-7. [pmid: 10457044].
15 Centers for Disease Control and Prevention (U.S.) NCfHSUS. ICD-9-CM, international classification of diseases, ninth revision, clinical modification. U.S. Dept. of Health and Human Services Centers for Disease Control and Prevention Health Care Financing Administration.
16 Hamer S, Collinson G. Achieving evidence-based practice: a handbook for practitioners. 2nd ed. Edinburgh; New York: Baillìere Tindall Elsevier; 2005.
17 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
18 Moore DS, McCabe GP. Introduction to the practice of statistics. 4th ed. New York: W.H. Freeman and Co.; 2003.
19 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
20 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. Sep 15. 2003;22(17):2693-710. [pmid: 12939780].
21 Kahn HA, Sempos CT. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). USA: Oxford University Press; 1989.
22 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London: NetLibrary, Inc. BMJ Books; 2001.
23 Dawson B, Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). 3rd ed. New York: Lange Medical Books-McGraw-Hill; 2004.
24 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
25 Hoerger TJ, Harris R, Hicks KA, et al. Screening for type 2 diabetes mellitus: a cost-effectiveness analysis. Ann Intern Med. May 4. 2004;140(9):689-99. [pmid: 15126252].