# Appendixes

Appendix A. Analytic Framework

Appendix B. Exact Search Strings

Appendix C. List of Excluded Studies

Appendix D. Technical Expert Panel Members and Affiliation

Appendix E. Data Abstraction Forms

Appendix F. Evidence Tables