# Appendix I: Evidence Tables

Table 1 Evidence Table. Study design, Oncotype DX™

Study, Year | Country | Study period (data collection period) | Study Type | Population size, N | Blinded (Y/N) | Study purpose
Chang,2007^55^ | UK and USA | 2000-2004 | retrospective | 72 | NR | Validation
Cobleigh, 2005^47^ | USA | 1979-1999 | retrospective | 78 | NR | Development
Cronin, 2004^44^ | USA | NR | retrospective | 62 | NR | Protocols development
Cronin, 2007^45^ | USA | NA | Analytic validity | NR | NR | Analytic validity
Esteva, 2005^48^ | USA | 1978-1995 | retrospective | 149 | NR | Validation
Fan, 2006^79^ | Netherlands | NR | retrospective | Poor prognosis, 180 | NA | Validation
| | | | Good prognosis, 115
Gianni, 2005^49^ | Italy | 1998-2002 | prospective | INT-Milan, 95 | NA | Validation
Habel, 2006^50^ | USA | 1985-1994 | case control | Cases, 220 | NR | Validation
| | | | Controls, 570
Hornberger, 2005^67^ | USA | NR | retrospective | NSABP B-14, 668 | NR
| | | | NSABP B-20, 651
Lyman, 2007^75^ | USA | NR | retrospective | NSABP B-14, 668 | NR
| | | | NSABP B-20, 651
Mina, 2006^51^ | NR | NR | retrospective | Gene profile, 45 | NA | Validation
| | | | Parent trial, 70
Oratz, in press^56^ | NR | NR | retrospective | 74 | NR | Validation
Paik, 2004*^28^ | USA | 1982-1988 | retrospective | 668 | NR | Validation
Paik, 2006*^53^ | USA | 1988-1993 | retrospective | Tamoxifen treated, 227 | NR | Validation
| | | | Tamoxifen and chemotherapy, 424

* Supplemental information

NR = not reported; INT= Italian National Cancer Institute of Milan, Italy; NA = not applicable; NSABP = The National Surgical Adjuvant Breast and Bowel Project

Table 2 Evidence Table. Study population characteristics, Oncotype DX™

Study, Year | Intervention | General Characteristics | Diagnosis(es) | Treatments and Outcomes
Chang,2007^55^ | | Age: mean 49 y | TG: Well 2 (2.8%) | Treatments:
| | Menopausal status: | TG: Moderate 29 (40.3%) | a: Docetaxel at 100 mg/m 128 2 was given every 3 weeks for a total of 4 cycles, and clinical response was assessed after the fourth cycle, at 12 weeks.
| | pre: n=26 (53.1%) | TG: Poor 41 (56.9%) | s, a: Primary surgery and standard adjuvant therapy were then administered
| | post: n=23 (46.9) | H: Ductal 67 (93.1%) | Outcome:
| | Race, n (%): | H: Lobular 4 (5.6%) | CR (complete disappearance of the tumor), 12 (16.7%)
| | W: 37 (52) | H: Mucinous 1 (1.4%) | PR (decrease in unidimensional size by at least 30%), 41 (56.9%)
| | B: 19 (27) | ER+: 47 (69.1%) | PD (an increase of more than 25%), 2 (2.8%)
| | H: 11 (16) | ER-: 21 (30.9%) | SD (any response that does not meet the definition of CR, PR, or PD), 17 (23.6%)
| | A: 4 (6) | PR+: 38 (58.5%) | Complete pathologic response 2 (3.2%); Others 61 (96.8%)
| | UK: 1 | PR-: 27 (41.5%) | Unknown 9;
| | Exclusion criteria: NR | PR Unknown: 7; | Relapse: Yes 13 (20.0%); No 52 (80.0%) Unknown 7
| | | HER-2+: 7 (13.5%)
| | | HER-2-: 45 (86.5%)
| | | HER-2 Unknown: 20
| | | Palpable nodes: Yes 7 (10.0%)
| | | Palpable nodes: No 63 (90.0%)
| | | Palpable nodes: Unknown 2
Cobleigh, 2005^47^ | | Age, mean y (range) SD: 57 (33–86) 13 | TS 0–2; 26/78 (33%) | Treatments:
| | Menopausal status: NR | TS 2–5; 28/78 (36%) | h: tamoxifen Yes; 42/78 (54%)
| | Race, n (%): NR | TS >5; 24/78 (31%) | h: tamoxifen No; 36/78 (46%)
| | Exclusion criteria:; - evidence of metastatic disease; - <10 positive nodes; - <5% of specimen shows tumor involvement; - no evidence of invasive breast cancer | Rush (B-R) TG 1; 22/78 (29%) | a: chemotherapy (cyclophosphamide, methotrexate, fluorouracil) Yes; 62/78 (80%)
| | | Rush (B-R) TG 2; 28/78 (36%) | a: chemotherapy No; 16/78 (20%)
| | | Rush (B-R) TG 3; 28/78 (36%) | Outcomes: NR
| | | Genomic Health (B-R) TG 1; 11/78 (14%)
| | | Genomic Health (B-R) TG 2; 37/78 (47%)
| | | Genomic Health (B-R) TG 3; 30/78 (38%)LN# 0–9; 0/78 (0%)
| | | LN# 10–15; 40/78 (51%)
| | | LN# 15–20; 18/78 (23%)
| | | LN# 20–30; 12/78 (15%)
| | | LN# >30; 8/78 (10%)
Cronin, 2004 ^44^ | There are no patient characteristics reported in this article. This is a study of analytic validity.
Cronin, 2007 ^45^ | There are no patient characteristics reported in this article. This is a study of analytic validity.
Esteva, 2005^48^ | None | Age, mean y, SD, median y: 58.0, 11.5, 59.0 | mean TS(cm) 2.3 | NR
| | Menopausal status: | median TS(cm) 2.0
| | Pre; 122/149 (84.6%) | standard deviation(cm) 1.1
| | Post; 27/149 (18.1%) | B-R TG 1; 18/149 (12.1%)
| | Race, n (%): | B-R TG 2; 86/149 (57.5%)
| | W, 126 (84.6) | B-R TG 3; 45/149 (30.2%)
| | H, 8 (5.4) | ER -; 46/149 (30.9%)
| | B 10 (6.7) | ER +; 103/149 (69.1%)
| | A 5 (3.4) | (HER2) -; 124/149 (83.2%)
| | Exclusion criteria:; - specimen shows <5% invasive tumor; - insufficient RNA extracted from specimen; - RT-PCR signal for genes outside the specifications for the assay; - evidence of axillary lymph node involvement; - use of adjuvant systemic therapy; - follow up for <5 years | (HER2) +; 25/149 (16.8%)
| | | PR -; 99/149 (66.4%)
| | | PR +; 50/149 (33.6%)
Fan, 2006 ^79^ | Poor prognosis | Age, n (%) | H I (good); 19/180 (11%) | Treatment:
| | <40yrs 52 (29) | H II (intermediate); 56/180 (31%) | h Yes; 23/180 (13%)
| | 40–44yrs, 41 (23) | H III (poor); 105/180 (58%) | h No; 157/180 (87%)
| | 45–49yrs, 55 (31) | TS ≤20mm; 84/180 (47%) | a Yes; 66/180 (37%)
| | ≥50yrs; 32 (18) | TS >20mm; 96/180 (53%) | a No; 114/180 (63%)
| | Menopausal status: NR | LN# 0; 91/180 (51%) | s Breast conserving; 97/180 (54%)
| | Race: NR | LN#1–3; 63/180 (35%) | s mastectomy; 83/180 (46%)
| | Exclusion criteria:; - Previous history of cancer (except non-melanoma skin cancer); - Apical axillary lymph node involvement; - Age at diagnosis >52 years; - Tumor >5 cm in diameter at pathological examination | LN# ≥4; 26/180 (14%) | Outcome: NR
| | | ER -; 66/180 (37%)
| | | ER +; 114/180 (63%)
| | | VI Absent; 108/180 (60%)
| | | VI 1–3 vessels; 18/180 (10%)
| | | VI >3 vessels; 54/180 (30%)
| | | Diagnostic method: RT-PCR
| Good prognosis | Age, n (%) | H I (good); 56/115 (49%) | Treatment:
| | <40yrs, 11 (10) | H II (intermediate); 45/115 (39%) | h: Yes; 17/115 (15%)
| | 40–44yrs, 44 (38) | H III (poor); 14/115 (12%) | h: No; 88/115 (85%)
| | 45–49yrs, 43 (37) | TS ≤20mm; 71/115 (62%) | a: Yes; 44/115 (38%)
| | ≥50yrs, 17 (15) | TS >20mm; 44/115 (38%) | a: No; 71/115 (62%)
| | Menopausal status: NR | LN# 0; 60/115 (52%) | s: Breast conserving; 64/115 (56%)
| | Race: NR | LN# 1–3; 43/115 (37%) | s: mastectomy; 51/115 (44%)
| | Exclusion criteria: see poor prognosis | LN# ≥4; 12/115 (10%) | Outcome: NR
| | | ER-; 3/115 (3%)
| | | ER +; 112/115 (97%)
| | | VI Absent; 77/115 (67%)
| | | VI 1–3 vessels; 12/115 (10%)
| | | VI >3 vessels; 26/115 (23%)
| | | Diagnostic method: RT-PCR
Gianni, 2005^49^ | INT-Milan | Age, mean y (range) SD: 49.9 (29–65) 9.0 | T1 0/89 (0%) | Treatments:
| Doxorubicin (60mg/m2) + Paclitaxel (200mg/m2) every 3 weeks X3 | Menopausal status: NR | T2 1/89 (1%) | s: Mastectomy; 79/89 (89%)
| Followed by paclitaxel (80mg/m2) weekly X12 | Race, n (%): NR | T3 2/89 (2%) | s: Quadrantectomy; 8/89 (9%)
| | Exclusion criteria: NR | T4a 0/89 (0%) | No surgery; 2/89 (2%)
| | | T4b 70/89 (79%) | Outcomes:
| | | T4d (inflammatory breast Ca) 16/89 (18%) | CR; 17/89 (19%)
| | | LNO 14/89 (16%) | PR; 57/89 (64%)
| | | LN1 51/89 (57%) | SD; 13/89 (15%)
| | | LN2 24/89 (27 %) | PD; 2/89 (2%)
| | | Supraclavicular LN 14/89 (16%) | pCR; 11/89 (12%)
| | | TG 1; 21/80 (24%)
| | | TG 2; 49/89 (55%)
| | | TG 3; 19/89 (21%)
| | | ER -; 31/89 (35%)
| | | ER +; 52/89 (58%)
| | | ER Not Assessable 6/89 (7%)
| MDACC-Houston | Age, mean y (range) SD: 53.1 (29–79) 11.7 | T1 7/82 (9%) | Treatments:
| 12 weeks of paclitaxel | Menopausal status: NR | T2 46/82 (56%) | s: Mastectomy; 48/89 (59%)
| followed by fluorouracil, doxorubicn and cyclophosphamide (FAC) X4 courses | Race, n (%): NR | T3 15/82 (18%) | s: Quadrantectomy;33/89 (40%)
| | Exclusion criteria: NR | T4a 1/82 (1%) | No surgery; 1/89 (1%)
| | | T4b 6/82 (7%) | Outcomes:
| | | T4d (inflammatory breast Ca) 7/82 (9%) | CR; 28/82 (34%)
| | | Nodal status | PR; 40/82 (49%)
| | | N0 28/82 (34%) | SD; 13/82 (16%)
| | | N1 38/82 (46%) | PD; 1/82 (1%)
| | | N2 8/82 (10 %) | pCR; 21/82 (26%)
| | | Supraclavicular LN 8/82 (10%)
| | | TG 1; 2/82 (3%)
| | | TG 2; 31/82 (37%)
| | | TG 3; 50/82 (60%)
| | | ER -; 48/82 (58%)
| | | ER +; 32/82 (39%)
| | | ER Not Assessable 3/82 (4%)
Habel, 2006^50^ | Cases | Age, n (%): | TS < 1 cm, 49 (22) | Treatments:
| | <40, 17 (8) | TS 1.1–2 cm, 93 (42) | h: Tamoxifen, 64 (26)
| | 40–49, 42 (19) | TS 2.1–4 cm, 72 (33) | Outcomes:
| | 50–59, 64 (29) | TS > 4 cm, 6 (3) | RS <18, 57 (26%)
| | 60–74, 97 (44) | TG well diff, 25 (11) | RS 18-3, 54 (25%)
| | Menopausal status: NR | TG mod diff, 92 (42) | RS > 31, 109 (50%)
| | Race, n (%) | ER+, 168 (76)
| | W, 172 (78) | ER-, 52 (24)
| | H, 7 (3) | Poor diff, 103 (47)
| | B, 20 (9)
| | A, 21 (10)
| | Exclusion criteria:; - positive node status; - diagnosed at or after 75 years of age; - initial disease treated with chemotherapy; - inflammatory or bilateral breast cancer or evidence of metastases; - prior invasive cancer; - unknown/unconfirmed treatment with tamoxifen
| Controls | Age, n (%): | TS < 1 cm, 193 (34) | Treatments:
| | <40, 23 (4) | TS 1.1–2 cm, 255 (45) | h: Tamoxifen, 177 (31)
| | 40–49, 127 (22) | TS 2.1–4 cm, 114 (20) | Outcomes:
| | 50–59, 152 (27) | TS > 4 cm, 8 (1) | RS <18, 322 (56%)
| | 60–74, 268 (47) | TG well diff, 175 (31) | RS 18-3, 108 (19%)
| | Menopausal status: NR | TG mod diff, 261 (46) | RS > 31, 140 (25%)
| | Race, n (%) | ER+, 514 (90)
| | W, 457 (810) | ER-, 56 (10)
| | H, 13 (2) | Poor diff, 134 (23)
| | B, 47 (8)
| | A, 53 (9)
| | Exclusion criteria: see cases
Hornberger, 2005 ^67^ | There are no patient characteristics reported in this article. This was a study on the economics of using a recurrence score to predict distant recurrence-free survival in patients with early-stage breast cancer.
Lyman, 2007 ^75^ | High RS (≥31) | Age: NR | DR: Tamoxifen alone, 38.3%; Tamoxifen + chemo, 11.1% | NR
| | Menopausal status: NR
| Intermediate RS (18–30) | Race: NR | DR: Tamoxifen alone, 17.8%; Tamoxifen + chemo, 10.1%
| Low RS (<18) | Exclusion criteria: NR | DR: Tamoxifen alone, 3.7%; Tamoxifen + chemo, 5%
Mina, 2006 ^51^‡ | Parent trial (Miller, 2005), n=70 | Age, mean y (range): 50 (30–65) | TS: 6 cm | NA
| | Menopausal status: NR | TG: NR
| | Race/ethnicity, n (%): NR | ER+: 40 (57)
| | Exclusion criteria: NA | HER2+: 14 (20)
| | | pCR: 9 (13)
| | | Pathologically negative nodes: 37 (53)
| | | Inflammatory disease 14 (20)
| | | Palpable lymph nodes: 33 (47)
| Gene Profile subset, n=45 | Age, mean y (range): 49 (29–64) | TS: 6.8 cm (2.3–21) | Treatments:
| | Menopausal status: NR | TG: well differentiated 11 (24); mod differentiated 12 (27); poor differentiated 22 (49) | a: sequential doxorubicin a:, 75 mg/M2 ea 2weeks for 3 cycles; docetaxel (T) 40 mg/M2 1weeks for 6 cycles
| | Race/ethnicity, n (%): NR | ER+: 26 (57) | a: definitive surgery was at the completion of all chemotherapy
| | Exclusion criteria: NR | HER2+: 8 (18) | r: at the discretion of the treating oncologist
| | | pCR: 6 (13) | h: Tamoxifin was recommended for all ER+ pts
| | | Pathologically negative nodes: 23 (51) | Outcomes'
| | | Inflammatory disease 9 (20)
| | | Palpable lymph nodes: 21 (47)
Oratz, in press ^56^ | | Median age (range): 54 (35–77) | TS (cm) 0–1.0; 32/68 (47%) | NR
| | Menopausal status: NR | TS (cm) 1.1–2.0; 28/68 (41%)
| | Race, n (%): NR | TS (cm) 2.1–3.0; 8/68 (12%)
| | Exclusion criteria: NR | TG 1; 30/68 (44%)
| | | TG 2; 24/68 (35%)
| | | TG 3; 14/68 (21%)
| | | LN+/LN—: 0/74
| | | ER+/ER-:74/0
Paik, 2004^28^ | NSABP B-14, Genomic Health populations: n = 668 | Age, n (%): | TS 0–1.0; 109 (16%) | NR
| | <50y, 194 (29) | TS 1.1–2.0; 305 (46%)
| | 50 to 60y, 173 (26) | TS 2.1–4.0; 220 (33%)
| | ≥60y, 301 (45) | TS ≥4.1; 34 (5%)
| | Menopausal status: NR
| | Race/ethnicity, n (%):
| | W, 615 (92)
| | B, 31 (5)
| | O, 22 (3)
| | Exclusion criteria:; - insufficient tumor as assessed by histopathology <5% overall tissue; - insufficient RNA < 0.5μg; - weak TR-PCR signal (avg cycle threshold for the reference genes >35)
| NSABP B-14, remaining population, n = 1949 | Age, n (%): | TS 0–1.0; 366 (19%) | NR
| | <50y, 618 (32) | TS 1.1–2.0; 877 (45%)
| | 50 to 60y, 583 (30) | TS 2.1–4.0; 635 (32%)
| | ≥60y, 748 (38) | TS ≥4.1; 71 (4%)
| | Menopausal status: NR
| | Race/ethnicity, n (%):
| | W, 1763 (90)
| | B, 87 (5)
| | O, 99 (5)
| | Exclusion criteria: NR
| All B-14 patients, n = 2617 | Age, n (%): | TS 0–1.0; 475 (18%)
| | <50y, 812 (31) | TS 1.1–2.0; 1182 (45%)
| | 50 to 60y, 756 (29) | TS 2.1–4.0; 855 (33%)
| | ≥60y, 1049 (40) | TS ≥4.1; 105 (4%)
| | Menopausal status: NR
| | Race/ethnicity, n (%):
| | W, 2378 (91)
| | B, 118 (4)
| | O, 121 (5)
| | Exclusion criteria: NR
Paik, 2006^53^ | TAM treated and chemotherapy treated NSABP-B20 patients, n=651 | Age, n (%): | TS 0–1 cm, 110 (17) | Treatments: NA
| | <40, 63 (10) | TS 1.1–2 cm, 318 (49) | Outcomes:
| | 40–49, 226 (35) | TS 2.1–4 cm, 196 (30) | RS <18, 353
| | 50–59, 166 (25) | TS >4 cm, 24 (4) | RS 18-3, 134
| | >60, 196 (30) | TG well diff, 77 (13) | RS > 31, 164
| | Menopausal status: NR | TG mod diff, 339 (59)
| | Race/ethnicity, n (%): NR | TG poor diff, 163 (28)
| | Exclusion criteria:; - insufficient tumor as assessed by histopathology <5% overall tissue; - insufficient RNA < 0.5μg; - weak TR-PCR signal (avg cycle threshold for the reference genes >35) | ER 10–49 fmol/mg, 261 (40)
| | | ER 50–99 fmol/mg, 153 (23)
| | | ER 100–199 fmol/mg, 122 (19)
| | | ER >200 fmol/mg, 115 (18)
| | | PR 0–9 fmol/mg, 105 (16)
| | | PR 10–49 fmol/mg, 113 (17)
| | | PR 50–99 fmol/mg, 97 (15)
| | | PR 100–199 fmol/mg, 110 (17)
| | | PR >200 fmol/mg, 226 (35)
| TAM treated, n=227 | Age, mean y (range): NR | NR | Treatments:
| | Menopausal status: NR | | h: Tamoxifen
| | Race/ethnicity, n (%): NR | | Outcomes:
| | Exclusion criteria: see all patients | | RS <18, 135; RFS 10 year-96.8%
| | | | RS 18-3, 45; RFS 10 year-90.9%
| | | | RS > 31, 47; RFS 10 year-60.5%
| TAM and chemotherapy, n=424 | Age, mean y (range): NR | NR | Treatments:
| | Menopausal status: NR | | h: Tamoxifen
| | Race/ethnicity, n (%): NR | | a: cyclophosphamide, methotrexeate, and fluorouracil (CMF) OR methotrexeate and fluorouracil (MF)
| | Exclusion criteria: see all patients | | Outcomes:
| | | | RS <18, 218; RFS 10 year-95.6%
| | | | RS 18-3, 89; RFS 10 year-89.1%
| | | | RS > 31, 117; RFS 10 year-88.1%

* Diagnoses: H = histology/histologic type; TS = tumor size/diameter; LN# = # of Lymph nodes at primary diagnosis; LN = lymph node status; TG = tumor grade; ER = estrogen receptor status; HER = HER neu status; PR = Progesterone receptor status; SP = S-phase fraction; Pl = ploidy; VI = vascular invasion; PTS = site of primary tumor; HR = hormonal status, ER or PR or both; DR = distant recurrence; LI lymphatic infiltrate

† Treatments: H = hormonal; A = adjuvant; S = surgical; R = radiation

‡ Treatment outcomes: OS = overall survival; RFS = relapse-free survival (first disease relapse, irrespective of site); CR = complete response; PR = partial response; RS: recurrence score; SD = stable disease; PD = progressive disease; pCR = complete pathologic response; D = death

W=white; B=black; H=Hispanic; A=Asian; NR=not reported; RNA=ribonucleic acid; NSABP= National Surgical Adjuvant Breast and Bowel Project; CMF= cyclophosphamide, methotrexeate, and fluorouracil; MF= methotrexeate and fluorouracil; TAM=tamoxifen

Table 3 Evidence Table. Analytic validity, Oncotype DX™

Study, year | Measure | Conclusions
Chang, 2007^55^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens. Out of the 97 eligible samples the analysis was carried on 80 samples* | The RT-PCR technology provides a potential platform for a predictive test using small amounts of routinely processed specimens (core biopsies)
| Methods:
| - Standard Oncotype DX assay protocols were developed; - Methods for IHC not described; - The degree of concordance between IHC and RT-PCR with respect to ER, PR, and HER-2 was assessed graphically and by the kappa statistic; - Positivity from RT-PCR analysis was assigned by the following expression levels:
| ER, >6.5.0 CT
| PR, > 5.5 CT
| HER2, > 11.5 CT
| Results:
| - 80 patients out of 97 successfully analyzed, for the following reasons*:
| Tumor content < 5%: 16 /97 patients (16.5%)
| Poor RNA yield: 1/80 patient (1.2%)
| Successful assays: 80 /97 (82.4%)
| - Agreement between IHC vs RT-PCR:
| ER, k = 1.00, (95% CI = 1.00 to 1.00)
| PR, k= 0.57, (95% CI = 0.37 to 0.77)
| HER2, k= 0.74, (95% CI = 0.45 to 1.00)
| *Of the 80 patients that were assayed however clinical information was available for 72 cases
Cobleigh, 2005^47^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens. Out of the 86 eligible samples the analysis was carried on 78 samples. | The accuracy and specificity of this RT-PCR assay of formalin-fixed, paraffin embedded tumor tissue was supported by comparison of the results of RT-PCR assay of RNA and IHC assay of protein for ER, PR, and HER2;
| Methods:
| - Standard Oncotype DX assay protocols were used; - Immunohistochemistry (IHC) of ER, PR, HER2/neu and Ki-67 by standard biotin-streptavidin method with the appropriate antibodies (DAKO, CA, USA):; - The ER staining were defined as positive if staining of any intensity was seen in more than 10% of cells; - ER positivity from RT-PCR analysis was assigned to expression levels > 6.5 CT; - Pearson's correlation for co-expressed genes evaluation
| Results:
| - 78 patients out of 86 successfully analyzed, for the following reasons:
| Clinically ineligible: 1 stage VI;
| Tumor content < 5%: 7 patients
| Successful assays: 78/85 (91.7%)
| - Correlation between two distinct probe-prime sets for ER in RT-PCR: r =0.96; - Agreement between IHC vs RT-PCR:
| ER, k = 0.83
| PR, k= 0.40
| HER2, = 0.67
| Ki-67/MIB1, = 0.22
| - Pearson's correlation for gene pairs:
| KRT5 and KRT17 (r = 0.86)
| LPL and RBP4 (r = 0.82)
| HER2 and GRB7 (r = 0.82);
Cronin, 2004^44^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens.
| Methods:
| - Standard Oncotype DX assay protocols were developed; - Methods for IHC an d FISH not described; - ER positivity from RT-PCR analysis was assigned to expression levels > 8 CT; - Pearson's correlation for co-expressed genes evaluation and correlation between FFPE and frozen specimen
| Results:
| - ER status by RT-PCR:
| ER-positive: 79% (49 out of 62 tumors)
| ER-negative: 21% (13 out of 62 tumors)
| - ER status, IHC vs RT-PCR comparison:
| 58 concordant samples
| 24ER positive by RT-PCR were negative by IHC
| - Agreement between IHC vs RT-PCR:
| ER, 93.5%
| PR, 84%
| HER2, 100%
| - Pearson's correlation for gene pairs:
| KRT5 and KRT17 (r = 0.85)
| LPL and RBP4 (r = 0.84)
| HER2 and GRB7 (r = 0.71)
| ER1 and GATA23 (r = 0.60)
| - Comparison between FFPE and frozen specimens, 48 genes:
| Correlation = 0.91, p value < 0.0001)
Cronin, 2007^45^ | Context: This study used the Oncotype DX assay | Authors reported that the following procedures a currently performed to assure the reproducibility of the assay:
| - The following analytic components of the assay were addressed: | A standard RNA control sample is assayed at least once per batch of patient (46 samples)
| Limits of detection (LOD) | PCR controls are run in every assay plate
| Limits of quantification (LOQ) | RT-PCR failures are excluded from analysis
| Amplification efficiency | Expression values are assigned when at least 2 of 3 assay wells provide acceptable RT-PCR results
| Dynamic range linearity | All 21 genes must have an expression value assigned for an RS to be calculated and reported
| Accuracy and precision
| Reproducibility
| Methods:
| - Repeated negative sample measurement and a serial dilutions experiment, using a pooled reference RNA were performed for each gene, to assess LOD, LOQ, amplification efficiency, dynamic range linearity, and accuracy and precision; - Repeated measurements of 2 aliquots of a single RNA sample across multiple days, operators, RT-PCR plates, 7900HT instruments, and liquid-handling robots were performed to assess individual gene and RS reproducibility; - In the linearity study cDNA input varied over RNA equivalents between 2e-10 and 2000 ng per reaction; in all other experiments cDNA input was equivalent to 2 ng RNA; - The linearity response was assessed for each individual gene in the assay, by examining the SE from nonlinear polynomial regression; - ANOVA was used to asses precision variability due to plate and well within plate, treating plates and wells within plates at random; - Mixed-effect ANOVA was used to estimate components of variance due to days, plates within days, and within plates by treating operator, 7900HT instrument, and liquid-handling robot as fixed effects
| Results:
| - The LOD and the LOQ for all the genes proved to be well above the pre-specified limits of CT units (40 cycles):
| LOD ranged from 38.7 CT (RPLPO) to 40.0 CT (most of the genes in the assay)
| LOQ ranged from 36.9 CT (ERBB2) to 39.5 CT (GAPDH)
| - Amplification efficiencies for all the genes ranged from 75.3% (GAPDH) to 112.1% (BAG1), with values exceeding 100% due to the cumulative nature of the analysis along the sample-dilution series; - Assay linearity and dynamic range:
| 6 genes (ACTB, BAG1, CD68, ESR1, RPLP0, and TFRC), were linear over the entire RNA range
| 6 genes (BCL2, SCUBE2, GRB7, ERBB2, MMP11, and GAPDH), were linear over the entire RNA range tested, with an estimated maximal deviation from linearity below 1 CT over a linear range > 2000-fold, as specified by CLSI 4 genes (MYBL2, AURKA, BIRC5, MYBL2) were linear over a more restricted RNA concentration range of 2e-8 to 2000 ng, with an estimated maximal deviation from linearity below 1 CT over a linear range > 2000-fold, as specified by CLSI
| 1 gene (PR) was linear over a more restricted RNA concentration range of 2e-9 to 2000 ng
| 2 genes (CCNB1, GSTM1) were linear over a more restricted RNA concentration range of 2e-8 to 2000 ng
| 2 genes (CTSL2, GUSB) were linear over a more restricted RNA concentration range of 2e-7 to 2000 ng
| - Assay quantitative bias and precision at the 2-ng/well for the 16 cancer-related genes:
| range = -10% (BAG1) to 6% (CTSL2)
| estimated mean deviation = 0.3%
| CV of 5.7%
| - Assay quantitative bias and precision at the 2-ng/well for the 5 reference genes:
| range = -1.5% (GUSB) to 3.3% (ACTB)
| estimated mean deviation = 0.7%
| CV of 3.2%
| - Reproducibility, CT measurements SD for the individual genes:
| Total SD ranged from 0.06 to 0.15 CT units
| Between day SD ranged from 0 to 0.055 CT units
| Between plated SD ranged from 0 to 0.090 CT units
| Within plated SD ranged from 0.057 to 0.147 CT units
| At a CT of 30 a maximum SD of 0.15 translate into a CV of 0.5%
| The largest differences between operators, liquid handling robots, and 7900HT instruments, were < 0.5 CT
| - Reproducibility, CT measurements SD for the RS:
| Total SD was 0.792 RS units
| Between day SD was 0 RS units
| Between plated was 0 RS units
| - Within plated was 0.792 RS units
Esteva, 2005^48^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens. Out of the 220 eligible samples the analysis was carried on 149 samples
| Methods:
| - Standard Oncotype DX assay protocols were used; - IHC methods in Esteva et al., 2003^48^ and Wang et al., 2002^89^; - Positivity from RT-PCR analysis was assigned by the following expression levels:
| ER, >7.0 CT
| PR, > 6.0 CT
| HER2, > 11.5 CT
| - Concordance between RT-PCR and IHC results by Cohen's k statistics; - Logistic model for HER2 measurement by RT-PCR, IHC as a quantal response; - RT-PCR specificity and sensitivity, in comparison to IHC for HER2) were obtained at the different thresholds
| Results:
| - 149 patients out of 220 successfully analyzed, for the following reasons:
| Tumor content < 5%: 42 /220 patients (19.0%)*
| Poor RNA yield: 4/220 patients (1.8%)
| RT-PCR not within the specifications; 3 /220(1.3%)
| Low reference genes RT-PCR signal: 22/220 (10%)
| - Successful assays: 149 /220 (67.7%); - Agreement between IHC vs RT-PCR:
| ER, k = 0.80, (=+ 0.05)
| PR, k = 0.48
| HER2, k = 0.6, (=+ 0.08)
| - Agreement between IHC vs RT-PCR:
| Logistic model p value: < 0.001
| - HER2, RT-PCR > 11.50CT:
| Specificity: 77%
| Sensitivity: 84%
| - HER2, RT-PCR > 11.5 CT:
| Specificity: 89%
| Sensitivity: 84%
| - HER2, RT-PCR > 12.0 CT:
| Specificity: 95%
| Sensitivity: 68%
Gianni, 2005^49^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens. Out of the 95 eligible samples the analysis was carried on 89 samples.
| Methods:
| - Standard Oncotype DX assay protocols were used;; - Immunohistochemistry (IHC) of ER, PR by reagents from Lab Vision-Neomarkers (Fremont, CA); - The ER staining were defined as positive if staining of any intensity was seen in more than 10% of cells;; - ER positivity from RT-PCR analysis was assigned to expression levels > 6.5 CT;
| Results:; - 89 patients out of 95 successfully analyzed, for the following reasons:
| Poor RNA yield: 4 patients (4.2%);
| Tumor content < 5%: 2 patients (2.1%);
| Successful assays: 89/95 (93.7%);
| - Agreement between IHC vs RT-PCR:
| ER, k = 0.84, (95% CI = 0.71 to 0.96);
| PR, k= 0.71, (95% CI = 0.56 to 0.86);
Habel, 2006^50^ | Context: This study used the Oncotype DX assay, analyzing FFPE specimens; data about the success rate of the assay were reported.
| Methods:
| - Standard Oncotype DX assay protocols were used; - Pearson's correlation and ANOVA to assess within patients correlation and variability:
| 60 blocks that did not undergo macro-dissection from 20 (2 to 5 blocks per patient)
| 49 core biopsies or tumor resection blocks
| - ER positivity from RT-PCR analysis was assigned to expression levels > 6.5 CT
| Results:
| - After medical history review, FFPE blocks were available for 234 cases and 631 controls, for a total of 865 patients, who underwent pathological review:
| 59 patients needed macro-dissection
| 19 patients showed tumor content < 5% and were excluded from the study
| - The final analysis considered 220 cases and 570 controls, for a total 790 patients, resulting form a 7.9% loss due to insufficient tumor content and 1% failure rate of the RT-PCR assay; it is not clear which is the total with respect these percentage are expressed, since it was not reported; - RS (as a continuous value) standard deviation (SD) and Pearson's correlation observed in two unpublished study:
| Overall between blocks SD was 3.0 RS units
| For 16 of the 20 patients, the between blocks SD was < 2.5 RS units
| Pearson's correlation = 0.86
| Similar results from the second study
| - The concordance of ER status between RT-PCR and medical chart information:
| kappa = 0.49, 95% CI 0.41–0.56
| 115/122 of the discordances were patients classified as ER+ based on RT-PCR
Mina, 2006^51^ | Context: This study used the Oncotype DX assay, analyzing FFPE specimens. Out of the 70 eligible samples the analysis was carried on 45 samples. | Gene expression analysis on core biopsy samples is feasible;
| Methods:
| - Standard Oncotype DX assay protocols were used; - Immunohistochemistry (IHC) of ER, PR, HER2/neu and Ki-67 by standard biotin-streptavidin method with the appropriate antibodies (DAKO, CA, USA):
| anti-ER: mouse monoclonal 1 D5;
| anti-PR: mouse monoclonal PR636
| anti-Ki-67: mouse monoclonal MIB-1;
| HER2/neu: HercepTest;
| - The ER staining were defined as positive if staining of any intensity was seen in more than 10% of cells; - ER positivity from RT-PCR analysis was assigned to expression levels > 6.5 CT
| Results:
| - 45 patients out of 70 successfully analyzed, for the following reasons:
| No consent: 3 patients
| No specimen available: 10 patients
| Poor RNA yield: 9/57 patients (15.8%)
| Tumor content < 20%: 3/57 patients (5.3%)
| Successful assays: 45/57 patients (78.9%)
| - Reference genes showed smaller ranges of expression across samples, than the 16 cancer-related genes, especially the ER-related group (standard deviation in CT is reported:
| Normalization genes: b-actin = 0.56, GAPDH = 0.71, GUS = 0.75, RPLPO = 0.53, and TFRC = 0.64
| ER-related genes: ER = 2.72, PR = 2.27, Bcl2 = 1.41, and SCUBE2 = 2.45
| - ER status by RT-PCR:
| ER-positive: 64% (29 out of 45 tumors)
| ER-negative: 36% (16 out of 45 tumors)
| - ER status, IHC vs RT-PCR comparison:
| 41 concordant samples
| 2 ER positive by IHC were negative by RT-PCR
| 2 ER positive by RT-PCR were negative by IHC
| - Agreement data for PR, KI-67 and HER2/neu were not reported
Oratz, in press^56^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens. Out of the 74 eligible samples the analysis was carried on 72 samples
| Methods:
| - Standard Oncotype DX assay protocols were developed
| Results:
| - 72 patients out of 74 successfully analyzed, for the following reasons:
| Tumor content < 5%: 2 /74 patients (2.7%)
| Successful assays: 72 /74 (97.3%)
Paik, 2004*^28^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens. FFPE specimens were used. Out of the 754* eligible samples the analysis was carried on 668 samples
| Methods:
| - Standard Oncotype DX assay protocols were used; - ER and PR receptors proteins were measured by ligand-binding assays; - HER2 DNA was measured by a fluorescence in situ hybridization assay (PathVysion, Vysis); - Reproducibility within and between blocks was assessed by performing the 21-gene assay in five serial sections from six blocks in two patients
| Results:
| - 675 patients out of 754 successfully analyzed, for the following reasons:
| Tumor content < 5%: 79 /754 patients (89.5%)*
| Successful assays: 668 /675 (98.9%)
| - Reproducibility evaluation:
| 16 Cancer genes SD ranged from 0.07 to 0.21 CT units
| Within-block RS SD = 0.72 RS unit (95% CI = 0.55 to 1.04)
| Total within-patient SD (including between and within-block SD) = 2.2 RS units
| Similar variability in the RS was observed in reanalysis of clinical trial samples on separate days with different reagent lots (data not shown).
| * The total of 754 (79+675) patients was computed and not clearly reported in the study
Paik, 2006*^53^ | Context: This study used the Oncotype DX assay analyzing FFPE specimens. Out of the 670 eligible samples the analysis was carried on 651 samples
| Methods: Standard Oncotype DX assay protocols were used.
| Results:
| - A successful assay was obtained for 651 patients out of 670 for which a specimen block was available:
| Successful assays: 651/670 (97.2%)

FFPE = formalin fixed paraffin embedded; IHC = immunohistochemistry; RT-PCR = real time polymerase chain reaction; ER = estrogen receptor; PR = progesterone receptor; HER-2 = human epidermal growth factor receptor 2; CT = cycle threshold; RNA= ribonucleic acid; CI=confidence interval; FISH = Fluorescence In Situ Hybridization; LOD=limits of detection; LOQ=limits of quantification; ANOVA= analysis of variance; CLSI= Clinical and Laboratory Standards Institute; SD = standard deviation; RS = recurrence score; CV= coefficients of variation;

Table 4 Evidence Table. Clinical utility and validity, Oncotype DX™

Study, year | Measure | Conclusions
Chang,2007 ^55^ | Context: This study used the Oncotype DX assay and assessed its predictive utility | The authors have established molecular profiles for sensitivity to docetaxel adjuvant chemotherapy.
| End points: prediction of clinical response (by the RECIST method) to docetaxel treatment in women with breast cancer | The RT-PCR technology provides a potential platform for a predictive test of chemosensitivity using small amounts of routinely processed specimens.
| Methods:
| - The degree of concordance between IHC and RT-PCR with respect to ER, PR, and HER-2 was assessed graphically and by the kappa statistic;; - Logistic regression was used to evaluate the association between clinical complete response with:
| Various clinical variables;
| The expression levels of individual genes;
| The average expression levels for Oncotype DX gene groups;
| The Oncotype DX RS
| - Statistical significance in logistic regression analyses was determined by the likelihood ratio test;; - Area under the receiver operating characteristic curve (AUROC) was used to measure the accuracy of predictions from the logistic model;; - Expression relationships among genes were investigated through hierarchical cluster analysis using 1-Pearson r as the distance measure and pair-group average amalgamation
| Results:
| - Clinical CR was associated with lower expression of the ER gene group and higher expression of the proliferation gene group from the 21 gene assay;; - Clinical CR was more likely in the high RS risk group (P = 0.008);; - A 50 units increase in the RS showed an OR = 5 (95% CI = 1.3–6.0);; - A14 units increase in the RS showed an OR for a clinical complete response = 1.7 (95% CI = 1.15, 2.60);; - The accuracy with which RS predicted the response to adjuvant chemotherapy throughout the range of RS values was moderate (AUROC = 0.73)
Cobleigh, 2005^47^ | Context: This is one of the development studies of the Oncotype DX assay; | This study found that tumor gene expression was correlated with the likelihood of distant recurrence in patients who have invasive breast cancer and more than 10 positive nodes.
| End points: the likelihood of distant recurrence free survival in lymph nodes positive (> 10 nodes), ER positive and negative breast cancer patients | Tumor gene expression quantified by RT-PCR for 22 /203 genes was significantly correlated with distant relapse free survival (DRFS): unadjusted P-value < 0.05.
| Methods: Univariate and multivariate Cox proportional hazards models with stepwise variable selection and bootstrap resampling | The data generated in this study contributed to the development of the 21-gene assay and Recurrence Score algorithm.
| Results:
| Recurrence score classification:
| Low-risk group (RS < 18):
| 11 /78 patients (14%), rate of distant recurrence at 10 years of 29% (95% confidence interval, 0–53%)
| Intermediate-risk group (RS >18 and RS < 31):
| 19/78 patients (24%), rate of distant recurrence at 10 years of 72% (95% confidence interval, 38–88%)
| High-risk group (RS > 31):
| 48/78 patients (62%), rate of distant recurrence at 10 years of 80% (95% confidence interval, 63–89%).
Esteva, 2005^48^ | Context: This study used the Oncotype DX assay and assessed its prognostic utility. | The lack of validation of the assay observed in this study could be due to the following differences between the considered population and the NSABP B-14 population used in Paik et al 2004:
| End points (goals): | ER-positive and ER-negative patients were used;
| - Assess prognosis inpatients with node-negative breast cancer who did not receive systemic therapy using formalin-fixed, paraffin-embedded tissue; - Determine whether the quantitative RT-PCR data correlated with immunohistochemistry assay data regarding estrogen receptor, progesterone receptor, and HER 2 status. | ER-positive patients were not treated with tamoxifen;
| Methods: The Fleming and Harrington log-rank test and the Cox proportional hazards model, with the covariates age and tumor size, were used to test differences in distant recurrence among the distinct RS groups | An association between high nuclear grade and improved outcome was observed;
| Results: | Patients were from a single institution and the population could be affected by selection-bias.
| - No significant correlation was found between age, tumor size, or RS and distant recurrence-free survival; - No significant difference was found between the low-, intermediate-, and high risk groups in terms of 10-year distant recurrence free survival
Fan, 2006^79^ | Context: The study is a comparison of classification agreement among 5 different gene expression based predictors (70-genes, Oncotype DX, Wound-response, Intrinsic subtypes and two-gene ratio) using the 295 samples from the consecutive cohort originally used by van de Vijver, 2002,^25^ | Good but not perfect correlation between predictions, albeit surprising with different gene sets. Degree of prediction over and above “standard” clinical stratifiers is not clear - reclassification not done.
| Methods:
| - Cramer V statistics; - Kaplan-Meier survival analysis; - Multivariate Cox proportional hazards analysis, adjusting for age, tumor size, tumor grade, ER status, number of lymph node involved; - All analyses were performed using all the patients, as well as the ER positive patients subset (N=225); - NB: coefficients of clinical predictors were allowed to vary between models
| Results:
| - In multivariate Cox proportional hazards analysis all tests except the two-gene ratio were highly significant predictors of OS and DFS:
| 70 genes DFS HR = 3.4 (95%CI = 2.0–6.0), P value < 0.001
| Two-gene ratio DFS HR = 0.91 (95%CI = 0.6–1.3), P value = 0.62
| Oncotype OS HR = 4.3 (95%CI = 2.1–8.9), P value < 0.001
| 70 genes OS HR = 4.71 (95%CI = 2.02–11.0), P value < 0.001
| Two-gene ratio OS HR = 1.00 (95%CI = 0.61–1.63), P value = 0.99
| Oncotype DFS HR = 6.14 (95%CI = 1.84–20.4), P value = 0.003
| - ER status, tumor grade, tumor size, and lymph nodes were also significant predictors.; - Patients classification into dichotomized risks groups proved to be roughly similar, ranging from ~80% to ~40%:
| 70-genes and RS yielded a V= 0.60
| 70-genes and RS yielded an agreement of ~81% (239/295)
Gianni, 2005^49^ | Context: This study used the Oncotype DX assay and assessed its predictive utility | The authors identified a set of genes, which expression correlated with pCR to neoadjuvant doxorubicin and paclitaxel.
| End points (goal): to directly examine the correlation between RS and pCR, and to identify additional genes associated with pCR | The authors showed that the RS was strongly correlated with pCR.
| Methods:
| - Univariate analysis by logistic and probit regression was used to evaluate the association of gene expression and pCR; - Forward stepwise regression and bootstrap resampling were performed to assess robustness
| Results: The global likelihood ratio test assessing probit regression based models with and without the incorporation of the RS resulted in a P value of 0.005, showing a good discrimination of pCR by RS;
Habel, 2006^50^ | Context: This study used the Oncotype DX assay to assess its prognostic utility. | The RS was strongly associated with risk of breast
| End points: The risk of breast cancer-specific mortality among women with ER-positive, node-negative breast cancer. Patients were matched by age, race, year of diagnosis, and tamoxifen treatment. | cancer death among:
| Methods: | ER-positive patients treated with tamoxifen
| - Conditional logistic regression analysis was performed, adjusting for tumor size and grade; - Relative risks for RS, used as a continuous variable, was calculated for increments of 50 units; - Standard low (RS<18), intermediate (RS=19–31), and high (RS>31) risk groups were used; - Alternative RS risk stratification was obtained by RS quartiles; - RS was also used as a continuous variable in the models, assessing the association with the 10-years risk of death using increments of 50 RS units | ER-positive patients not treated with tamoxifen
| Results: | ER-negative patients
| - Multivariate analysis with continuous RS, tumor size and grade | Such associations remained after accounting for tumor size and grade.
| Tamoxifen treated (55 cases and 150 controls): RR = 5.3 (95% CI = 1.6–17.2), P value = 0.003 | The RS was able to identify a larger subset of patients with low risk of breast cancer death than it was possible with either of these standard prognostic indicators.
| Tamoxifen untreated (110 cases and 251 controls): RR = 2.4 (95% CI = 1.1–5.2), P value = 0.025
| - Overall the patients reclassification analysis according to RS, in combination with tumor size and grade, showed that RS is able to further stratify patients' risk beyond size and grade (see below)
| 10 yr risk of death with 95% CI in the Low risk group (RS <18):
| ER+, tamoxifen treated 2.8%, 95%CI (1.7–3.9)
| ER+, tamoxifen untreated 6.2%, 95%CI (4.5–7.9)
| 10 yr risk of death with 95% CI in the Intermediate risk (RS 18–30):
| ER+, tamoxifen treated 10.7%, 95%CI (6.3–14.9)
| ER+, tamoxifen untreated 17.8%, 95%CI (11.8–23.3)
| ER+, tamoxifen treated: RR (Intermediate vs low) = 4.0 (1.8–8.8)
| ER+, tamoxifen untreated: RR (Intermediate vs low) = 2.7 (1.5–5.0)
| 10 yr risk of death with 95% CI in the High risk (RS ≥31):
| ER+, tamoxifen treated 15.5%, 95%CI (7.6–22.8)
| ER+, tamoxifen untreated 19.9%, 95%CI (14.2–25.2)
| ER+, tamoxifen treated: RR (high vs low) = 6.2 (2.4–15.8)
| ER+, tamoxifen untreated: RR (high vs low) = 3.3 (1.8–5.9)
Hornberger, 2005 {#12933 | See evidence table 5
Lyman, 2007 ^75^ | See evidence table 5
Mina, 2006^51^ | Context: This study used the Oncotype DX assay to assess its predictive utility; | Although 22 genes were identified as being associated with pCR, given the large number of candidate genes tested, the likelihood of false discovery is high (13 genes were expected by chance alone).
| End points: complete pathological response (pCR) to primary chemotherapy with anthracycline- and taxanes; | The 22 predictive genes contain three major predefined clusters, angiogenesis-related genes, proliferation-related genes and invasion-related genes.
| Methods: | Though the Oncotype DX RS correlated with pCR in the INT Milan cohort of the Gianni et al study, this association was not found in the present study.
| - Generalized linear models with a logistic link function were used to assess the correlation of gene expression measurements with pCR.; - Logistic regression was used to examine the correlation RS with pCR.; - Logistic regression analysis was also performed to identify genes that correlated with inflammatory breast cancer (IBC).; - Correlation analyses of gene expression used Pearson linear correlation.; - Cluster analysis used 1-Pearson R squared as the distance metric and single linkage hierarchical clustering. | The authors failed to find a correlation between ER and pCR.
| Results:
| - No correlation between Oncotype DX RS and pCR was demonstrated (p = 0.67);; - The expression of 22 individual genes, out of 274, proved to be correlate with pCR (P value < 0.05), which could be grouped in 3 functionally distinct clusters:
| Angiogenesis-related genes
| Proliferation-related genes
| Invasion related genes
Oratz, in press^56^ | Context: Investigation of the impact of the Oncotype DX RS assay results on clinicians' treatment recommendations and on the actual treatment administered in patients with ER+, LN-, early (stage I or II) breast cancer; | The knowledge of the RS changed treatment recommendations and administration in patients with ER+, LN-, early breast cancer.
| End points: treatment recommendations prior to the RS knowledge were compared with recommendations after the results of the assay were known and to the treatment eventually administered; | An important finding is that the direction of the change was consistent with information provided by the RS.
| Methods:
| - Patients were stratified by:
| Standard RS risk categories;
| Treatment recommendation before knowledge of the RS;
| Treatment recommendation post knowledge of the RS;
| Actual administered treatment;
| - The odds ratio were computed to:
| Compare the likelihood of a change in the treatment recommendation given a low versus a high RS risk group;
| Evaluate the influence of the RS on the treatment actually administered.
| - Exact inference methods were used for significance testing of the odds ratio;
| Results:
| - The knowledge of the RS changed the clinicians' treatment recommendations in for 14 patients (20%):
| The odds of the physician treatment recommendation changing from hormonal therapy (HT) to chemotherapy (CT) were significantly higher (P = 0.0011) if the RS was high (odds 4:0) versus low (odds 1:18);
| The odds of the physician treatment recommendation changing from CT to HT were significantly higher (P = 0.0340) if the RS was low (odds 6:7) versus high (odds 0:10);
| - The knowledge of the RS changed the actual administered treatment in 17 patients (25%):
| The odds of CT treatment, given an initial physician treatment recommendation for HT, were significantly higher (P = 0.0474) if the RS was high (odds 2:2) versus low (odds 0:19);
| The odds of HT treatment, given an initial physician treatment recommendation for CT, were 20.3 times higher (P = 0.0130) if the RS was low (odds 9:4) versus high (odds 1:9);
Paik, 2004*^28^ | Context: This study used the Oncotype DX assay and assessed its prognostic utility. | The assay prognostic capability to quantify the likelihood of distant recurrence has been validated in tamoxifen-treated, lymph node-negative, ER-positive breast cancer.
| End points: the likelihood of distant recurrence and the Overall Survival in lymph nodes negative, ER positive breast cancer patients was considered
| Methods:
| - Comparison of the high and low risk groups by Kaplan-Meier analysis with Greenwood variance estimates; - Cox proportional-hazards models accounting for:
| Age (less than 50 years), clinical tumor size (less than 2cm), and RS (as continuous variable, hazard ratio for bins of 50 units);
| PR (as ordinal variable), ER (as ordinal variable), HER (as binary variable), age, clinical tumor size, tumor grade (1 pathologist), and RS;
| Results:
| - KM Estimates, 95% CI, and % of patients with distant recurrence at 10 years:
| Low=6.8–95%CI=4.0–9.6, 51%;
| Intermediate=14.3–95%CI=8.3–20.3, 22%;
| High =30.5–95%CI=23.6–37.4), 27%;
| P<0.001 for the comparison high versus low-risk category;
| - Overall survival, number of patients with death event over the total number of patients at risk:
| Low=70/338;
| Intermediate=48/149;
| High =71/181;
| - Age, size and RS:
| p-Value=0.001, Hazard Ratio =3.21 (95%CI=(2.23–4.61);
| - PR, ER, HER, age, size, grade, and RS:
| p-Value=0.001, Hazard Ratio =2.81 (95%CI=(1.70–4.64);
| Similar results with more than two categories of age and tumor size (data not shown);
Paik, 2006*^53^ | Context: This study used the Oncotype DX assay and validated the assay by assessing its predictive utility (prediction of chemotherapy benefit magnitude by RS). | The RS assay predicts the magnitude of chemotherapy benefit in women with node-negative, ER-positive breast cancer.
| End points: freedom from distant recurrence in women with ER-positive, node-negative breast cancer from NSABP B20. | If RS risk groups are considered:
| Methods: | a minimal benefit from chemotherapy is seen in the low risk group, however with large intervals;
| - Kaplan-Meier analysis with disease recurrence free survival (DRFS).; - Multivariate Cox proportional hazards models to evaluate the interaction between chemotherapy treatment and RS as a continuous variable.; - Models included RS, individual and grouped gene expression variables, patients' age, tumor size and grade, ER status, PR status.; - RS was used as a continuous variable, age size, grade, ER and PR were dichotomized; - Models with or without RS compared by the likelihood ratio test for interaction. | benefit is not assessable in the Intermediate risk group due to the uncertainty in the estimates;
| Results: | a large chemotherapy benefit is seen in the high risk group.
| - Kaplan-Meier Estimates of 10 Years DRFS for Tamoxifen-Treated Patients and Tamoxifen Plus Chemotherapy-Treated Patients (10-Year DRFS (%), 95% CI, number of patients):
| All patients:
| Tamoxifen alone: 87.8, 83.3% to 92.3%, 227
| Tamoxifen Plus Chemotherapy: 92.2, 89.4% to 94.9% 424
| Low risk (RS<18):
| Tamoxifen alone: 96.8 93.7% to 99.9%, 135
| Tamoxifen Plus Chemotherapy: 95.6 92.7% to 98.6%,218
| Intermediate risk (RS 18–30):
| Tamoxifen alone: 90.9 82.5% to 99.4% 45
| Tamoxifen Plus Chemotherapy: 89.1 82.4% to 95.9% 89
| High risk (RS>31):
| Tamoxifen alone: 60.5 46.2% to 74.8% 47
| Tamoxifen Plus Chemotherapy: 88.1 82.0% to 94.2% 117
| - Likelihood Ratio Tests for the Interaction of Chemotherapy Treatment With the Clinical Variables and the Gene Expression Variables, Assessable NSABP B20 Patients (n = 651)
| RS HR = 0.32 0, 95%CI = 11 0.94, P-value = 0.038
| - Benefit from chemotherapy usage by RS risk groups:
| Low risk (RS<18): RR = 1.31; 95% CI, 0.46 to 3.78, with a mean absolute decrease in distant recurrence rate at 10 years of 1.1% (SE, 2.2%)
| Intermediate risk (RS 18–31): RR = 0.61; 95% CI, 0.24 to 1.59, with a mean absolute increase in absolute risk of 1.8%
| High risk (RS>31): RR = 0.26; 95% CI, 0.13 to 0.53, with a mean absolute decrease in distant recurrence rate at 10 years of 27.6% (SE, 8.0%)
| - Similar trends were observed for freedom from locoregional and/or distant recurrence and overall survival (Figs A1 and A2, online-only appendix); - Similar results were observed when chemotherapy benefit was analyzed in the CMF and MF groups separately (data not shown);

RECIST = Response Evaluation Criteria in Solid Tumors; IHC = immunohistochemistry; RT-PCR = real time polymerase chain reaction; ER = estrogen receptor; PR = progesterone receptor; HER-2 = human epidermal growth factor receptor 2; AUROC=area under the receiver operating characteristic curve; CR = complete response; RS = recurrence score; OR = odds ratio; CI = confidence interval; DRFS = distant recurrence free survival; NSABP = The National Surgical Adjuvant Breast and Bowel Project; OS= overall survival; HR= hazard ratio; pCR = pathologic complete response; RR= relative risk; IBC= inflammatory breast cancer; INT= Italian National Cancer Institute of Milan, Italy; LN= lymph node; HT = hormonal therapy; CT = chemotherapy; KM= Kaplan Meier; SE = standard error; CMF= cyclophosphamide, methotrexeate, and fluorouracil; MF= methotrexeate and fluorouracil.

Table 5 Evidence Table. Critical appraisal of economic analyses of breast cancer gene expression testing

Dimension of Quality | Questions for Critical Appraisal^41^ | Answers
| | Hornberger, 2005^100^ | Lyman, 2007^101^ | Oestreicher, 2005^76^
Structure
Statement of decision problem or objective | Is there a clear statement of the decision problem? | Yes; Is a 21-Gene RT-PCR assay economically and clinically useful in assisting in classification of ER+, LN- early stage breast cancer patients and in determination of chemotherapy? | Yes; Is the use of a 21-Gene RT-PCR assay to assist in the risk classification and chemotherapy recommendation of early-stage breast cancer patients clinically and economically beneficial? | Yes; Is using the Netherlands Cancer Institute GEP assay versus NIH guidelines cost-effective for the identification of early stage breast cancer patients who would benefit from adjuvant chemotherapy?
| Is the objective of the evaluation and of the model specified and consistent with the stated decision problem? | Yes; to estimate the incremental benefits, costs, and cost-effectiveness of using a recurrence score based on the 21-Gene RT-PCR assay that would assign risk more accurately and help guide the decision to prescribe chemotherapy | Yes; to incorporate and extend validation results from previous studies of NSABP B-14 and B-20 into an economic model of the 21-gene expression signature to guide the use of adjuvant chemotherapy and hormonal therapy in patients with ER+, LN- early stage breast cancer | Yes; to assess the incremental coast and QALYs associated with use of the GEP assay compared to use of the NIH guidelines.
| Is the primary decision-maker specified? | Yes; physician | Yes; physician | Yes; physician
Statement of scope or perspective | Is the perspective for the model stated clearly? | Yes; Authors state that the model takes a “societal perspective considering survival, quality of life, and relevant costs.” | No. | Yes; Authors state that the model takes a “societal perspective for this analysis and follows the recommendations of the Panel on Cost-Effectiveness in Health and Medicine.”
| Are the model inputs consistent with the stated perspective? | Not entirely; the model does not include all costs that are relevant to a societal perspective, and specifically does not include direct non-medical costs (other than patient time) and indirect costs. | Not applicable since perspective is not stated. | Yes; the model includes costs that are relevant to a societal perspective, including direct medical costs and non-medical costs (e.g., lost wages from time spent traveling to treatment facilities and in treatment).
| Has the scope of the model been stated and justified? | Partly; Authors state the model includes survival, quality of life, and relevant costs, and forecasts outcomes over the patient's lifetime. Authors do not justify exclusion of some types of societal costs, and do not justify using a timeframe beyond the 10-year period for which recurrence data is available. | Partly; Authors indicate that the model includes clinical, economic, and quality of life outcomes, and projects the impact on life expectancy. Authors do not justify exclusion of some types of costs, and do not justify using a timeframe beyond the 10-year period for which recurrence data was available. | Yes; Authors state the model includes survival, quality of life, and relevant costs, and forecasts outcomes over the patient's lifetime. However, the model is based on a 6.7-year period for which recurrence data is available yet is projected over the patients' lifetime.
| Are the outcomes of the model consistent with the perspective, scope, and overall objective of the model? | Yes; Outcomes include survival in life-years, QALYs, and overall costs for breast cancer. | Yes; Outcomes include life-years saved, QALYs, and costs of cancer care. | Yes; Outcomes include expected proportion of distant recurrences prevented, QALYs, and overall costs for breast cancer.
Rationale for structure | Is the structure of the model consistent with a coherent theory of the health condition under evaluation? | Yes; The authors use a Markov model with transition states for: no recurrence; recurrence without metastatic progression; recurrence with metastatic progression; and death. | Uncertain; The authors do not provide sufficient information about the structure of the model. The model seems to be based on comparing outcomes for 3 adjuvant treatment strategies. Patients are classified based on RS score and then a treatment strategy is applied: Strategy 1 (all patients receive tamoxifen), Strategy 2 (all patients receive chemotherapy and tamoxifen), Strategy 3 (if RS classification = low risk, then only tamoxifen; if RS classification = intermediate or high risk, then chemotherapy and tamoxifen). | Yes; The authors use a Markov model with transition states for: no evidence of disease; distant recurrence; and death.
| Are the sources of data used to develop the structure of the model specified? | Yes | Uncertain because the structure of the model is not specified | Yes
| Are the causal relationships described by the model structure justified appropriately? | Yes; Authors use clinical data to determine recurrence rates and assume that all high risk patients will receive chemotherapy and all low risk patients will not receive chemotherapy. | Uncertain because the structure of the model is not specified | Yes; Authors use clinical data to determine recurrence rates and assume that all women classified as “poor prognosis” will receive chemotherapy and all women classified as “good prognosis” will not receive chemotherapy.
Structural Assumptions | Are the structural assumptions transparent and justified? | Yes | No | Yes
| Are the structural assumptions reasonable given the overall objective, perspective, and scope of the model? | Yes | Uncertain | Yes
Strategies/comparators | Is there a clear definition of the options under evaluation? | Yes; NCCN system as current standard versus the RT-PCR assay | Yes; clear description of treatment strategies as noted above | Yes; NIH clinical guidelines as the standard versus the Netherlands Cancer Institute GEP assay.
| Have all feasible and practical options been evaluated? | No; This analysis focuses only on comparing use of one test, the RT-PCR assay, to use of the NCCN guidelines. | No: This analysis focuses only on comparing outcomes of treatment guided by one test, the 21-gene expression signature, to outcomes associated with using tamoxifen alone or chemotherapy followed by tamoxifen. | No; This analysis focuses only on comparing use of one test, the Netherlands Cancer Institute GEP assay, to use of the NIH guidelines. A stated limitation by the authors is that other guidelines (e.g., NCCN) are available but were not used in this comparison.
| Is there justification for the exclusion of feasible options? | No | No | Partly; the authors state that the NCCN criteria are more conservative; they would have yielded higher cost and would have had higher sensitivity than the NIH guidelines. They suggest that using NCCN criteria would be unlikely to change the outcome of the model.
Model type | Is the chosen model type appropriate given the decision problem and specified causal relationships within the model? | Yes | Uncertain | Yes
Time horizon | Is the time horizon of the model sufficient to reflect all important differences between options? | Yes | Yes | Yes
| Are the time horizon of the model, the duration of the treatment, and the duration of the treatment effect described and justified? | Yes; The model forecasts outcomes over the patient's lifetime and assumes treatment time of 6 months, but does not explicitly state any assumption regarding the duration of the treatment effect. | Yes; The model estimates the impact on life expectancy and presents the assumed duration of treatment options, the longest of which was 24 weeks. | Yes; The model forecasts outcomes over the patient's lifetime and assumes initial treatment time of 6 months, but does not explicitly state any assumption regarding the duration of the treatment effect.
Disease states/pathways | Do the disease states (state transition model) or the pathways (decision tree model) reflect the underlying biological process of the disease in question and the impact of interventions? | Yes | Uncertain | Yes
Cycle length | Is the cycle length defined and justified in terms of the natural history of disease? | Yes; Cycle length is defined as 1 year. | No; Cycle length is not specified. | Yes; Cycle length is defined as 1 year.
Data
Data identification | Are the data identification methods transparent and appropriate given the objectives of the model? | Yes; The studies and cases used in the model are clearly referenced. | Yes; The authors cite previous work for some of the details. | Yes; The studies and assumptions used in the model are clearly referenced.
| Where choices have been made between data sources, are these justified appropriately? | Yes; Only NSABP B-14 data are used. This is justified by the limited amount of comparable sources of data with adequate followup. | Yes; The authors explain their use of data from NSABP B-20 and NSABP B-14. | Yes; The Netherlands Cancer Institute cohort data are used.
| Has particular attention been paid to identifying data for the important parameters in the model? | Yes; Authors focus on: 1) propensity to change chemotherapy decision based on recurrence score, 2) relative risk reduction of chemotherapy and tamoxifen versus tamoxifen only, 3) cost of chemotherapy, and 4) proportion of patients defined by NCCN as low risk. | Uncertain given the lack of information about the structure of the model | Yes; Authors focus on propensity to make chemotherapy decision based on the classification of low risk versus high-risk, relative risk reduction of chemotherapy, cost of chemotherapy, and proportion of patients defined by NIH criteria as low risk.
| Has the quality of the data been assessed appropriately? | Not reported | Not reported | Not reported
| Where expert opinion has been used, are the methods described and justified? | Not applicable | Not applicable | Not applicable
Data modeling | Is the data modeling methodology based on justifiable statistical and epidemiological techniques? | Yes | Uncertain given the lack of information about the structure of the model | Yes
Baseline Data | Is the choice of baseline data described and justified? | Yes; Percent chance of recurrence and treatment plans are cited and described. | Yes; Table 1 describes most of the baseline data. Other values are described throughout the paper | Yes; Probabilities of recurrence and treatment plans are described and justified.
| Are transition probabilities calculated appropriately? | Yes; Probabilities appear to be obtained from prior meta-analyses. | Uncertain, given the lack of information about the structure of the model. However, probabilities are taken from previous analysis of the 21-Gene RT-PCR assay | Yes; Probabilities were estimated from empirical analyses performed on patient level data from the Netherlands Cancer Institute cohort, which was also the population for a validation study of GEP.
| Has a half-cycle correction been applied to both cost and outcome? | Not reported | Not reported | Not reported
| If not, has this omission been justified? | No | No | No
Treatment effects | If relative treatment effects have been derived from trial data, have they been synthesized using appropriate techniques? | Yes; The authors use meta-analyses of clinical trials to estimate the relative risk reduction associated with chemotherapy plus tamoxifen versus tamoxifen alone. | Uncertain; Table 1 suggests that a single study is used as the source of estimates for relative effects of tamoxifen, chemotherapy plus tamoxifen, and RS-guided therapy. | Yes; The authors use the meta-analysis from the Early Breast Cancer Trialists' Group trial to estimate the relative risk reduction associated with chemotherapy.
| Have the methods and assumptions used to extrapolate short-term results to final outcomes been documented and justified? | Partly; The authors assume a constant recurrence rate over 10 years, but do not justify extrapolation beyond 10 years. | Not reported | Partly; The authors assume a constant recurrence rate over 6.7 years, but do not justify extrapolation beyond 6.7 years.
| Have alternative assumptions been explored through sensitivity analysis? | Yes, using sensitivity analysis and Monte Carlo simulation | Uncertain; Ranges for costs, healthy life expectancy, and utility with chemotherapy are given in Table 1. Although the authors do not state whether a sensitivity analysis was performed for these assumptions in particular, they indicate that a Monte Carlo analysis was performed. | Yes, a wide variety of assumptions has been explored using sensitivity analysis and Monte Carlo simulation
| Have assumptions regarding the continuing effect of treatment once treatment is complete been documented and justified? Have alternative assumptions been explored through sensitivity analysis? | Yes | Yes; The introduction also mentions ongoing investigations into the long-term effects of chemotherapy, particularly neurocognitive dysfunction and secondary malignancies | Yes
Quality of life weights (utilities) | Are the utilities incorporated into the model appropriate? | Yes; Table 3 lists several health-state utilities that are appropriate to include in the analysis. One limitation is that the sensitivity analysis considered only a relatively narrow range of estimates for each utility value. | Uncertain: The only health-state utility mentioned in this report is for “utility with chemotherapy.” No mention is made of any other relevant health-state utilities. | Yes; Table 1 listed several utilities that are appropriate to include in the analysis. These included: utilities for no adjuvant chemotherapy; adjuvant chemotherapy; no evidence of disease and distant recurrence
| Are the methods of derivation for the utilities justified? | Uncertain; The authors cite several references from peer-reviewed journals as the sources for the utility estimates, but they do not discuss any of the potential limitations of how those utilities were originally derived. | Partly: The authors report that they used a time trade-off method to estimate the impact of treatment strategies on health-related quality of life, but they provide no details about how the estimates were derived. | Unclear; The authors discuss their derivation of utilities and cite several references from peer-reviewed journals as the sources for the utility estimates. But they gave no explanation of the methods or scaling techniques that were used to derive the utility estimates. The utility values generally seemed very low when compared to the values typically assigned to serious health conditions.
Costs | Are the costs incorporated into the model justified? | Yes, but see the comment above regarding exclusion of some types of societal costs | Yes, but they provide no details about how the estimates were derived. | Yes, although it is unclear whether all relevant societal costs have been included.
| Has the source for all costs been described? | Yes | Yes; Most costs have been cited in Table 1. A reference is given for additional details. | Yes
| Have discount rates been described and justified given the target decision-maker? | Yes; The investigators discount both costs and survival by an annual rate of 3%. | Not reported | Yes; The investigators discounted costs and QALYs by an annual rate of 3%.
Data incorporation | Have all data incorporated into the model been described and referenced in sufficient detail? | Yes; Data inputs have been referenced and most have been described in sufficient detail. | No; The individual costs and recurrence probabilities have been justified and referenced. However, not all data inputs have been described. | Yes; Data inputs have been referenced and have been described in sufficient detail.
| Has the use of mutually inconsistent data been justified (i.e., are assumptions and choices appropriate?) | Not applicable | Not applicable | Not applicable
| Is the process of data incorporation transparent? | Yes; The incorporation of most costs into the model are described. However, calculation of the “follow-up” number is not described, although it seems to be incorporating treatment side-effects, monitoring for side-effects and end-of-life costs. | No; Not enough information is given to understand how the authors derived the estimates of “Costs” and “LYS” in Table 2 and “Expected Costs” from Figure 2. | Yes; The incorporation of costs into the model is described.
| If data have been incorporated as a distribution, has the choice of distribution for each parameter been described and justified? | Generally, point estimates are used, not distributions. As part of the sensitivity analysis, the investigators used a Monte Carlo probabilistic analysis, and referred to a technical appendix for the details. | Yes; The authors use a figure to show the distribution of distant recurrence estimates by RS. | Yes. The investigators conducted one-way sensitivity analysis varying the values of probabilities, costs and utilities on model results. As part of the sensitivity analysis, the investigators used a Monte Carlo probabilistic analysis.
| If data have been incorporated as distributions, is it clear that second order uncertainty is reflected? | Not reported | Not reported | Yes.
Assessment of uncertainty | Have methodological uncertainties been addressed by running alternative versions of the model with different methodological assumptions? | Not reported | Not reported | Yes. A number of alternative testing hypotheses and alternative testing strategies were considered in the model.
| Is there evidence that structural uncertainties have been addressed via sensitivity analysis? | Not reported | Not reported | Not reported.
| Has heterogeneity been dealt with by running the model separately for different subgroups? | Yes; The model considers NCCN low risk and NCCN high risk groups, and is applied to a cohort of 100 patients similar to those in the B-14 trial. | Yes; The model considers the B-14 and B-20 studies/ | Yes; The model considers low risk and high risk groups, and is applied to a hypothetical cohort of patients similar to those in the Netherlands Cancer Institute cohort. Additional prognostic groups using different combinations of GEP and NIH results were also considered.
| Are the methods of assessment of parameter uncertainty appropriate? | Yes | Yes | Yes
| If data are incorporated as point estimates, are the ranges used for sensitivity analysis stated clearly and justified? | Yes; The ranges are stated in Table 3, but are not fully justified. | Yes; The ranges for most data points are clearly stated in Table 1. | Yes; The ranges are stated in Table 1, but are not fully justified.
Internal consistency | Is there evidence that the mathematical logic of the model has been tested thoroughly before use? | Not reported | Not reported | Yes; the analysis was performed using a Microsoft Excel spreadsheet and then validated using decision analysis software.
External consistency | Are any counterintuitive results from the model explained and justified? | Not applicable | Not applicable | Not applicable
| If the model has been calibrated against independent data, have any differences been explained and justified? | Not reported | Not reported | Not reported
| Have the results of the model been compared with those of previous models and any differences in results explained? | Not reported | Not reported | Not reported

RT-PCR= reverse transcriptase polymerase chain reaction; ER=estrogen receptor; LN= lymph node; NSABP= National Surgical Adjuvant Breast and Bowel Project; GEP= gene expression programming; NIH= National Institute of Health; QALY= quality-adjusted life-year; RS= recurrence score; NCCN= National Comprehensive Cancer Network; LYS= life years saved.

Table 6 Evidence Table. Study design, MammaPrint^®^

Study, Year | Country | Study (data collection) period | Study Type | Population size, N | Blinded (Y/N) | Study purpose
Ach, 2007 ^57^ | | | | | | Inter-laboratory reproducibility
Buyse, 2006 ^59^ | France, Sweden, UK | 1980-1998 | retrospective | Clinical low risk/gene low risk, 52 | NR | Validation
| | | | Clinical low risk/gene high risk, 28
| | | | Clinical high risk/gene low risk, 59
| | | | Clinical high risk/gene high risk, 163
Fan, 2006 ^79^ | Netherlands | NR | retrospective | Poor prognosis, 180 | NA | Validation
| | | | Good prognosis, 115
Glas, 2006 ^58^ | Netherlands | NR | retrospective | 162 | NR | Development
van de Vijver, 2002 ^25^* | Netherlands | 1984-1995 | retrospective | Poor prognosis, 180 | NR | Validation
| | | | Good prognosis, 115
van't Veer ^21^* | Netherlands | 1983-1996 | retrospective | 98 (they say 98, but they are 97!!!!) | NR | Development and validation

* Supplemental information

NR = not reported; NA = not applicable

Table 7 Evidence Table. Study population characteristics, MammaPrintsup^®^

Study, Year | Intervention | General Characteristics | Diagnosis (es) [include details] | Treatments and Outcomes
Ach, 2007 ^57^ | There are not patient characteristics reported in this article. This is a study of analytic validity
Buyse, 2006^59^ | Clinical low risk/gene low risk§ n=52 | Age, n (%) | TS <1 cm, 5 (9) | Treatment: NR
| | < 41, 8 (15) | TS 1–2 cm, 30 (58) | Outcome: Proportion alive at 10y (95% CI), 0.88 (0.74 to 0.95)
| | 41–50, 36 (69) | TS 2–5 cm, 17 (33)
| | 51–60, 8 (15) | TG good diff, 22 (43)
| | Menopausal status: NR | TG Int diff, 29 (56)
| | Race: NR | TG poor diff, 0 (0)
| | Exclusion criteria:; - >61 years Old; - >T1–T2(>5cm); - previous malignancy (except basal cell carcinoma); - bilateral synchronous breast | TG UK, 1 (2)
| | | ER+, 52 (100)
| | | ER-, 0 (0)
| | | Diagnostic method: clinical and microarray
| Clinical low risk/gene high risk n=28 | Age, n (%) | TS <1 cm, 4 (14) | Treatment: NR
| | < 41, 1 (4) | TS 1–2 cm, 12 (43) | Outcome: Proportion alive at 10y (95% CI), 0.69 (0.45 to 0.84)
| | 41–50, 22 (78) | TS 2–5 cm, 12 (43)
| | 51–60, 5 (18) | TG good diff, 12 (43)
| | Menopausal status: NR | TG Int diff,16 (57)
| | Race: NR | TG poor diff, 0 (0)
| | Exclusion criteria: see clinical low risk/gene low risk | TG UK, 0 (0)
| | | ER+, 28 (100)
| | | ER-, 0 (0)
| | | Diagnostic method: clinical and microarray
| Clinical high risk/gene low risk§ n=59 | Age, n (%) | TS <1 cm, 0 (0) | Treatment: NR
| | < 41, 9 (15) | TS 1–2 cm, 17 (29) | Outcome: Proportion alive at 10y (95% CI), 0.89 (0.45 to 0.95)
| | 41–50, 20 (34) | TS 2–5 cm, 42 (71)
| | 51–60, 30 (51) | TG good diff, 7 (12)
| | Menopausal status: NR | TG Int diff, 41 (69)
| | Race: NR | TG poor diff, 11 (18)
| | Exclusion criteria: see clinical low risk/gene low risk | TG UK, 0 (0)
| | | ER+, 54 (91)
| | | ER-, 5 (9)
| | | Diagnostic method: clinical and microarray
| Clinical high risk/gene high risk§ n=163 | Age, n (%) | TS <1 cm, 2 (1) | Treatment: NR
| | < 41, 40 (24) | TS 1–2 cm, 40 (24) | Outcome: Proportion alive at 10y (95% CI), 0.69 (0.61 to 0.76)
| | 41–50, 67 (41) | TS 2–5 cm, 121 (74)
| | 51–60, 56 (34) | TG good diff, 6 (3)
| | Menopausal status: NR | TG Int diff, 39 (23)
| | Race: NR | TG poor diff, 113 (69)
| | Exclusion criteria: see clinical low risk/gene low risk | TG UK, 5 (3)
| | | ER+, 78 (48)
| | | ER-, 85 (52)
| | | Diagnostic method: clinical and microarray
Fan, 2006^79§^ | Poor prognosis | Age, n (%) | H I (good); 19/180 (11%) | Treatment:
| | <40yrs 52 (29) | H II (intermediate); 56/180 (31%) | h Yes; 23/180 (13%)
| | 40–44yrs, 41 (23) | H III (poor); 105/180 (58%) | h No; 157/180 (87%)
| | 45–49yrs, 55 (31) | TS ≤20mm; 84/180 (47%) | a Yes; 66/180 (37%)
| | ≥50yrs; 32 (18) | TS >20mm; 96/180 (53%) | a No; 114/180 (63%)
| | Menopausal status: NR | LN# 0; 91/180 (51%) | s Breast conserving; 97/180 (54%)
| | Race: NR | LN#1–3; 63/180 (35%) | s mastectomy; 83/180 (46%)
| | Exclusion criteria:; - Previous history of cancer (except non-melanoma skin cancer); - Apical axillary lymph node involvement; - Age at diagnosis >52 years; - Tumor >5 cm in diameter at pathological examination | LN# ≥4; 26/180 (14%) | Outcome: NR
| | | ER -; 66/180 (37%)
| | | ER +; 114/180 (63%)
| | | VI Absent; 108/180 (60%)
| | | VI 1–3 vessels; 18/180 (10%)
| | | VI >3 vessels; 54/180 (30%)
| | | Diagnostic method: RT-PCR
| Good prognosis | Age, n (%) | H I (good); 56/115 (49%) | Treatment:
| | <40yrs, 11 (10) | H II (intermediate); 45/115 (39%) | h: Yes; 17/115 (15%)
| | 40–44yrs, 44 (38) | H III (poor); 14/115 (12%) | h: No; 88/115 (85%)
| | 45–49yrs, 43 (37) | TS ≤20mm; 71/115 (62%) | a: Yes; 44/115 (38%)
| | ≥50yrs, 17 (15) | TS >20mm; 44/115 (38%) | a: No; 71/115 (62%)
| | Menopausal status: NR | LN# 0; 60/115 (52%) | s: Breast conserving; 64/115 (56%)
| | Race: NR | LN# 1–3; 43/115 (37%) | s: mastectomy; 51/115 (44%)
| | Exclusion criteria: see poor prognosis | LN# ≥4; 12/115 (10%) | Outcome: NR
| | | ER-; 3/115 (3%)
| | | ER +; 112/115 (97%)
| | | VI Absent; 77/115 (67%)
| | | VI 1–3 vessels; 12/115 (10%)
| | | VI >3 vessels; 26/115 (23%)
| | | Diagnostic method: RT-PCR
Glas, 2006^58‖^ | There are not patient characteristics reported in this article. This is a study of analytic validity
van de Vijver, 2002^25a^ | Poor prognosis | Age, n (%) | H I (good); 19/180 (11%) | Treatment:
| | <40yrs; 52 (29) | H II (intermediate); 56/180 (31%) | h: Yes; 23/180 (13%)
| | 40–44yrs; 41 (23) | H III (poor); 105/180 (58%) | h: No; 157/180 (87%)
| | 45–49yrs; 55 (31) | TS ≤20mm; 84/180 (47%) | a: Yes; 66/180 (37%)
| | ≥50yrs; 32 (18) | TS >20mm; 96/180 (53%) | a: No; 114/180 (63%)
| | Menopausal status: NR | LN# 0; 91/180 (51%) | s: Breast conserving; 97/180 (54%)
| | Race: NR | LN#1–3; 63/180 (35%) | s: mastectomy; 83/180 (46%)
| | Exclusion criteria:; - Previous history of cancer (except non-melanoma skin cancer); - Apical axillary lymph node involvement; - Age at diagnosis >52 years; - Tumor >5 cm in diameter at pathological examination | LN# ≥4; 26/180 (14%) | Outcome: NR
| | | ER -; 66/180 (37%)
| | | ER +; 114/180 (63%)
| | | VI Absent; 108/180 (60%)
| | | VI 1–3 vessels; 18/180 (10%)
| | | VI >3 vessels; 54/180 (30%)
| Good prognosis | Age, n (%) | H I (good); 56/115 (49%) | Treatment:
| | <40yrs; 11 (10) | H II (intermediate); 45/115 (39%) | h: Yes; 17/115 (15%)
| | 40–44yrs; 44 (38) | H III (poor); 14/115 (12%) | h: No; 88/115 (85%)
| | 45–49yrs; 43 (37) | TS ≤20mm; 71/115 (62%) | a: Yes; 44/115 (38%)
| | ≥50yrs; 17 (15) | TS >20mm; 44/115 (38%) | a: No; 71/115 (62%)
| | Menopausal status: NR | LN# 0; 60/115 (52%) | s: Breast conserving; 64/115 (56%)
| | Race: NR | LN# 1–3; 43/115 (37%) | s: mastectomy; 51/115 (44%)
| | Exclusion criteria: see poor prognosis | LN# ≥4; 12/115 (10%) | Outcome: NR
| | | ER-; 3/115 (3%)
| | | ER +; 112/115 (97%)
| | | VI Absent; 77/115 (67%)
| | | VI 1–3 vessels; 12/115 (10%)
| | | VI >3 vessels; 26/115 (23%)
| ^a^ Poor and Good prognosis groups using the optimized sensitivity threshold from van't Veer 2002^21^
van't Veer, 2002^21b^ | | Mean age, y (range), SD: | H I (good); 11/97 (11.3%) | Treatment:
| | 44.9 (28–54), 6.9 | H II (intermediate); 26/97 (26.8%) | h: hormonal therapy (3 patients)
| | (for the 78 patients used to develop the test + 19 of the validation; BRCA1 patients non included) | H III (poor); 60/97 (61.8%) | a: Adjuvant Chemotherapy (3 patients)
| | Menopausal status: NR | TS ≤20mm; 57/97 (58.8%) | s: Modified radical mastectomy (35 patients
| | Race: NR | TS >20mm; 40/97 (41.2%) | s: Breast conserving treatment (72 patients) S: axillary lymph-node dissection (all 97 patients)
| | Exclusion criteria:; - Tumor larger than 5cm (>T2); - metastases (M1); - Older than 55yrs at diagnosis; - previous malignancy; - not diagnosed between 1983 and 1996 | LN# 0; 97/97 (100%) | Outcome: Metastases within 5yrs from surgery: 51 patient did NOT develop metastases; 46 patient developed metastases
| | | ER -; 29/97 (29.8%) (by IHC, <10% positive nuclei)
| | | ER +; 68/97 (70.2%) (by IHC, >10% positive nuclei)
| | | PR -; 41/97 (42.3%) (by IHC, <10% positive nuclei)
| | | PR +v; 56/97 (57.7%) (by IHC, >10% positive nuclei)
| | | VI Absent; 69/97 (71.2%)
| | | VI Present 28/97 (28.8%)
| | | LI Absent; 18/97 (18.5%)
| | | LI Present 79/97 (81.5%)
| ^b^ Development (78 patients): classified in the Poor group=35; classified in the Good group=43; Validation (19 patients): classified in the Poor group=5; classified in the Good group=14 with the optimized sensitivity threshold

* Diagnoses: H = histology/histologic type; TS = tumor size/diameter; LN# = # of Lymph nodes at primary diagnosis; LN = lymph node status; TG = tumor grade; ER = estrogen receptor status; HER = HER neu status; PR = Progesterone receptor status; SP = S-phase fraction; Pl = ploidy; VI = vascular invasion; PTS = site of primary tumor; HR = hormonal status, ER or PR or both; DR = distant recurrence; LI lymphotic infiltrate

† Treatments: H = hormonal; A = adjuvant; S = surgical; R = radiation

‡ Treatment outcomes: OS = overall survival; RFS = relapse-free survival (first disease relapse, irrespective of site); CR = complete response; PR = partial response; RS: recurrence score; SD = stable disease; PD = progressive disease; PCR = pathologic complete response; D = death

§ Data not reported in article, referred directly to van de Vijver, 2002^25^.

‖ Data not reported in article, referred directly to van't Veer, 2002^21^.

NR= not reported; CI= confidence interval; RT-PCR= reverse transcriptase polymerase chain reaction.

Table 8 Evidence Table. Analytic validity, MammaPrint^®^

Study, year | Measure | Conclusions
Ach, 2007, ^57^ | Context: MammaPrint assay was used to evaluate the intra- and inter-laboratory reproducibility of the assay involving three laboratories. Variation in RNA amplification and labeling, hybridization and wash, and slide scanning was measured on 4 tumors, dye-flip design, 24 slides (8 per site). | The authors showed very low influence on sample-to-reference ratios based on averaged triplicate measurements in the two-color experiments;
| Methods: To assess reproducibility in this study, ANOVA P values and Pearson's correlation were used. | RNA labeling was the largest contributor to inter-laboratory variation;
| Results:; - Replicate hybridizations Pearson's correlation at the same site: | Overall, despite this variation, measurement of 70-gene signature in three different laboratories was found to be highly robust;
| For 1 tumor in 1 sub-array = 0.983
| For 2 tumor in 2 sub-arrays = 0.988
| For all the other technical replicates > 0.993
| - Scanning reproducibility across sites:
| Cy3: Pearson correlation >0.995, slope = 0.97
| Cy5: less reproducible (data not shown)
| - 70-gene signature reproducibility:
| No differences between hybridization sites
| No differences between hybridization days (regardless of site)
| Statistically significant difference (P value <0.05) between labeling sites for two tumors
Buyse, 2006^59^ | Context: The MammaPrint assay was used. Out of the 403 eligible samples the analysis was carried on 326 samples.
| Methods: Standard MammaPrint assay protocols were used, using fresh-frozen specimens
| Results:; - 326 patients out of 403 successfully analyzed, for the following reasons:
| Poor RNA yield: 77/403 patients (19.1%)
| Successful assays: 326/403 patients (80.9%)
Glas, 2006^58^ | Context: MammaPrint assay development through re-analysis of patients from the van't Veer^21^ and van de Vijver^25^ cohorts for which an RNA aliquot or the frozen specimen were available. A different reference RNA was used, as well as a different quantification method. | The authors demonstrate for the first time that microarray technology can be used as a reliable diagnostic tool;
| Methods:; - 162 total samples from fresh-frozen specimens: | The MammaPrint assay performed similarly to the original 70-genes signature
| 84 patients from the van de Vijver^25^ cohort
| All 78 patients form the van't Veer cohort^21^
| A combination of the two population above: 145 (84+61) LN-negative patients
| Re-analysis on 49 patients
| - Dye-swap hybridization over reference RNA from 105 sample from the van de Vijver series (balanced in terms of Good and Poor); - Relative gene expression quantified as the error-weighted average over triplicate spots of the log10 ratio; - Pearson's correlation to assess correlation with original data and reproducibility; - ANOVA analysis to model variability in repeated experiments using the 70 genes of the signature; - Reproducibility in time was assessed by repeated measurements of RNA aliquots:
| 1 patient with cosine correlation to Good profile = 0.61, for 12 months
| 1 patient with cosine correlation to Good profile = -0.44, for 12 months
| 1 border-line with cosine correlation to Good profile = 0.43, for 4 months
| Results:; - Comparison to original 70-gene signature data, Pearson's Correlations and in repeated measurements:
| 78 van't Veer^21^ patients, r = 0.92, p value < 0.0001
| 145 (84+61) van de Vijver^25^ LN-negative patients: r = 0.88 p value < .0001
| 49 patients analyzed twice, r = 0.995
| - Reproducibility results from ANOVA analysis:
| No variation within individuals (p value = 0.96)
| Significant variation between individuals and genes
| - Reproducibility in time analysis results:
| For both patients assessed over a period of 12 months measurements SD was 0.028 of the cosine correlation
| For the 1 border-line sample assessed over a period of 4 months measurements SD was 0.027 of the cosine correlation
| This latter sample was miss-classified 6 times (15%)
van't Veer^21^ | Context: In this study the 70-gene signature was developed and no analytic validity data about the MammaPrint assay are reported.
van de Vijver^25^ | Context: In this study the 70-gene signature was developed and no analytic validity data about the MammaPrint assay are reported.

RNA= ribonucleic acid; ANOVA= analysis of variance; Cy3= the green fluorescent dyes commonly used in two colors design microarray hybridization; Cy5= the red fluorescent dyes commonly used in two colors design microarray hybridization; LN= lymph node; SD= standard deviation;

Table 9 Evidence Table. Clinical utility and validity, MammaPrint^®^

Study, year | Measure | Conclusions
Buyse, 2006^59^ | Context: This study was designed to test the validation of the MammaPrint assay through the TRANSBIG consortium multicenter, multinational collaborative study involving 5 distinct institutions. | MammaPrint is a better predictor of TTM than Age, Size, Grade, ER, Adjuvant!, NPI, St Gallen;
| End points: OS, RFS (any recurrence as event); TTM (time to metastases as first relapse) | St Gallen is a better predictor of DFS than MammaPrint
| Methods:; - The Kaplan-Meier product limit estimator was used in survival analyses.; - Hazard ratios were formulated to compare the high-risk group with the low-risk group.; - Hazard ratios heterogeneity across institutions was evaluated by chi-square test with four degrees of freedom.; - Gene signature hazard ratios were stratified by clinical risk and vice versa.; - Follow-up duration impact on hazard ratios was analyzed by censoring all observations at increasing time points.; - Sensitivity and specificity were estimated for distant metastases within 5 years and for death within 10 years.; - Time-dependent receiver operating characteristic (ROC) curves were computed by using the tumor expression level for the 70-genes signature and the 10-year survival probability for the Adjuvant! Software. | MammaPrint is a better predictor for OS than Age, Size, Grade, ER, Adjuvant!, NPI, St Gallen;
| Results:; - Kaplan-Maier analysis stratified by MammaPrint and Adjuvant (% of patients with distant recurrence): | The signature remained a statistically significant prognostic factor for TTM and OS even after adjustment for various risk classifications methods based on clinicopathologic factors;
| Good(R>0.4), Adjuvant!Low: 52 patients | The lack of statistical significance for DFS was explained by the fact that the signature was originally developed using TTM as the endpoint.
| OS(10years): 0.88 (0.74 to 0.95) | Overall the 70-gene signature adds independent prognostic information to clinicopathologic risk assessment for node-negative untreated patients with early breast cancer;
| Good(R>0.4)Adjuvant!High: 59 patients | Clinical risk hazard ratios, adjusted for the gene signature were not significant, suggesting that most of their prognostic utility is subsumed by the gene signature;
| OS(10years): 0.89 (0.77 to 0.95)
| Poor(R<0.4)Adjuvant!Low: 28 patients
| OS(10years): 0.69 (0.45 to 0.84)
| Poor(R<0.4)Adjuvant!High: 163 patients
| OS(10years): 0.69 (0.61 to 0.76)
| - Hazard Ratios (unadjusted):
| MammaPrint:
| TTM=2.32 (95% CI = 1.35–4.00)
| DFS=1.50 (95% CI = 1.04–2.16)
| OS=2.79 (95% CI = 1.60–4.87)
| Adjuvant:
| TTM=1.68 (95% CI = 95% CI = 0.92 to 3.07)
| DFS=1.30 (95% CI = 95% CI = 0.86 to 1.95);
| OS=1.67 (95% CI = 95% CI =0.93 to 2.98)
| - Hazard Ratios (adjusted):
| MammaPrint adjusted by St Gallen:
| TTM=2.15 (95% CI = 1.25 to 3.71)
| DFS=1.41 (95% CI = 0.97 to 2.06)
| OS=2.69 (95% CI = 1.53 to 4.73)
| MammaPrint adjusted by NPI:
| TTM=2.15 (95% CI =1.19 to 3.92)
| DFS=1.45 (95% CI = 0.97 to 2.16)
| OS=2.89 (95% CI = 1.58 to 5.29)
| MammaPrint adjusted by Adjuvant:
| TTM= 2.13 (95% CI = 1.19 to 3.82)
| DFS= 1.36 (95% CI = 0.91 to 2.03)
| OS= 2.63 (95% CI =1.45 to 4.79)
| Adjuvant Adjusted by MammaPrint:
| TTM=1.26 (95% CI = 0.66 to 2.40);
| DFS=1.03 (95% CI = 0.67 to 1.59)
| OS=1.08 (95% CI = 0.59 to 1.99)
| - Sensitivity for development of metastases within 5 years:
| Gene signature 0.90 (0.78 to 0.95)
| Adjuvant! software 0.87 (0.75 to 0.94)
| Nottingham Prognostic Index 0.79 (0.65 to 0.88)
| St Gallen criteria 0.96 (0.86 to 0.99)
| - Specificity for development of metastases within 5 years:
| Gene signature 0.42 (0.36 to 0.48)
| Adjuvant! software 0.29 (0.24 to 0.35)
| Nottingham Prognostic Index 0.48 (0.42 to 0.54)
| St Gallen criteria 0.10 (0.07 to 0.14)
| - Sensitivity for death within 10 years:
| Gene signature 0.84 (0.73 to 0.92)
| Adjuvant! software 0.82 (0.71 to 0.90)
| Nottingham Prognostic Index 0.70 (0.57 to 0.80)
| St Gallen criteria 0.95 (0.86 to 0.98)
| - Specificity for death within 10 years:
| Gene signature 0.42 (0.36 to 0.48)
| Adjuvant! software 0.29 (0.23 to 0.35)
| Nottingham Prognostic Index 0.47 (0.41 to 0.53)
| St Gallen criteria 0.10 (0.07 to 0.14)
| - ROC area under the curve for MammaPrint:
| TTM: 0.681
| OS: 0.659
| - ROC area under the curve for Adjuvant:
| TTM: 0.648
| OS: 0.576
| - Adjustments for clinical risk using different cutoff points produced only minor changes in the adjusted gene signature hazard ratios
Espinosa, 2005^80^ | Context: 70-genes signature partial validation using RT-PCR analysis: 60 out of the 70 genes of the signatures plus 4 additional genes. The study was conducted to reproduce the results obtained by microarray by an alternative method using 96 patients with full follow-up and frozen specimen from a single institution | qRT-PCR reproduced the results obtained with microarrays for the 70-genes prognostic profile in women with early-stage breast cancer
| End points: Relapse-free survival (RFS), and overall survival (OS) measured by relapses dichotomization (regardless of the site of first relapse): low-risk if the patient survived 2 years or longer, or high risk otherwise | Both RFS and OS were significantly longer in patients harboring a good-prognosis gene profile.
| Methods:; - The RT-PCR based 70-genes signature surrogate: was obtained as follows:
| Gene by gene qRT-PCR normalization,
| Gene expression categorization using the cutoff value of 0,
| Distance/similarity coefficient calculation for each patient,
| Similarity cutoff value optimization to yield the highest significance in log-rank tests for DFS
| - The Kaplan-Meier product limit method was used in survival analysis and significance was assessed by bilateral log-rank test; - The Mann-Whitney test was used to compare patients'; characteristics; - The Fisher's exact test was used to compare categorical variables; - Multivariate Cox proportional regression analysis was performed by adjusting by ER status, lymph node status, number of positive lymph nodes (less or more than 3) and gene profile
| Results:; - Kaplan-Meier estimates for the Good prognosis profile:
| RFS after 70 months: 85%
| OS after 70 months: 97%
| Log-rank test P value = 0.03
| - Kaplan-Meier estimates for the Bad prognosis profile:
| RFS after 70 months: 62%
| OS after 70 months: 72%
| Log-rank test P value = 0.002
| - Results of multivariate Cox proportional regression analysis:
| OS by lymph node status, HR = 1.2; 95%CI = 1.09 to 1.36
| OS by the 70-genes profile HR = 6.3; 95%CI = 1.28 to 31.07
| DFS by lymph node number, HR = 1.13; 95%CI = 1.05 to 1.25
| DFS by the 70-genes profile HR = 2.74, 95%CI = 1.13 to 6.61
Fan, 2006^79^ | Context: The study is a comparison of classification agreement among 5 different gene expression based predictors (70-genes, Oncotype DX™, Wound-response, Intrinsic subtypes and two-gene ratio) using the 295 samples from the consecutive cohort originally used by van de Vijver 2002^25^. | Good but not perfect correlation between predictions, albeit surprising with different gene sets. Degree of prediction over and above “standard” clinical stratifiers is not clear - reclassification not done.
| Methods:; - Cramer V statistics; - Kaplan-Meier survival analysis; - Multivariate Cox proportional hazards analysis, adjusting for age, tumor size, tumor grade, ER status, number of lymph node involved; - All analyses were performed using all the patients, as well as the ER positive patients subset (N=225); - NB: coefficients of clinical predictors were allowed to vary between models
| Results:; - In multivariate Cox proportional hazards analysis all tests except the two-gene ratio were highly significant predictors of OS and DFS:
| 70 genes DFS HR = 3.4 (95%CI = 2.0–6.0), P value < 0.001
| Two-gene ratio DFS HR = 0.91 (95%CI = 0.6–1.3), P value = 0.62
| Oncotype OS HR = 4.3 (95%CI = 2.1–8.9), P value < 0.001
| 70 genes OS HR = 4.71 (95%CI = 2.02–11.0), P value < 0.001
| Two-gene ratio OS HR = 1.00 (95%CI = 0.61–1.63), P value = 0.99
| Oncotype DFS HR = 6.14 (95%CI = 1.84–20.4), P value = 0.003
| - ER status, tumor grade, tumor size, and lymph nodes were also significant predictors.; - Patients classification into dichotomized risks groups proved to be roughly similar, ranging from ~80% to ~40%:
| 70-genes and RS yielded a V= 0.60
| 70-genes and RS yielded an agreement of ~81% (239/295)
Glas, 2006^58^ | Context: MammaPrint assay development through reanalysis of patients from the van't Veer^21^ and van de Vijver^25^ cohorts for which an RNA aliquot or the frozen specimen were available. A different reference RNA was used, as well as a different quantification method. | The authors demonstrate for the first time that microarray technology can be used as a reliable diagnostic tool
| Methods:; - 162 lymph node negative, young breast cancer patients (<55 years), who did not received adjuvant therapy.; - All 78 patients form the van't Veer 2002^21^ cohort were available and used to reestablish the 70-genes expression profile, using the same procedures originally used and the same correlation to the signature (0.4).; - 145 sample from the van de Vijver^25^ cohort (61 also in van't Veer^21^) were used and a higher correlation was used for classification purposes (0.55). | The MammaPrint assay performed similarly to the original 70-genes signature and is, therefore, an excellent tool to predict outcome of disease in breast cancer patients
| Results:; - Comparison between MammaPrint and the original 70-genes signature using all the 78 patients from the van't Veer^21^ series for the risk of developing a metastasis as first relapse event within 5 years from surgery:
| MammaPrint OR = 13.95 (95%CI = 3.9–44)
| Original 70-genes signature OR = 15, 95%CI = 2.1 to 19)
| - 7 patients out of 78 were classified differently by MammaPrint with respect to the original 70-genes signature:
| 2 good prognosis patients were correctly classified by MammaPrint, but not by the original 70-genes signature
| 1 poor prognosis patient was correctly classified by MammaPrint, but not by the original 70-genes signature
| 2 poor prognosis patient s were misclassified by MammaPrint, but not by the original 70-genes signature
| 2 good prognosis patients were misclassified by MammaPrint, but not by the original 70-genes signature
| - Comparison between MammaPrint and the original 70-genes signature using 145/151 LN negative patients from the van de Vijver^25^ series for the risk of developing a metastasis as first relapse event within 5 years from surgery:
| HR for MammaPrint = 5.6 (95%CI = 2.4–7.3, p value = 0.0001)
| - The probability of remaining free of metastases at 5 years was not different between MammaPrint and the original 70-genes signature, with a p value = 0.89 in log-rank test; - Similar results were obtained for OS
van de Vijver, 2002^25^ | Context: 70-genes signature partial validation using a gene expression array containing 25,000 features was used to evaluate the prognostic performance of the 70-genes signature in a consecutive series of 295 young women (< 53 years at diagnosis), with early stage (I–II), ER-positive or negative, node positive or negative breast cancer, who received or not adjuvant therapy (hormonal therapy, chemotherapy or both). | The 70-genes signatures is a better predictor of the risk of distant metastases than standard clinical predictors
| End point: distant metastases as first relapse event; patients were censored on the date of the last follow-up visit, death from causes other than breast cancer, the recurrence of local or regional disease, or the development of a second primary cancer, including contralateral breast cancer and Overall Survival (OS)
| In this study, 61 of the 78 patients of the van't Veer^21^ cohort were included.
| Methods:; - Kaplan-Meier analysis on the time form surgery to the first metastasis event or to censoring.; - Survival curves were compared by the log-rank test.; - Values are expressed as means ±SE, calculated according to the method of Tsiatis.; - All SEs were calculated with use of the sandwich estimator.; - Cox proportional-hazards regression analysis was used to investigate the association between the correlation coefficient (C1) and metastases by adjusting for other clinical variables (tumor grade, vascular invasion, and number of involved axillary's lymph-nodes: 0 versus 1 to 3 or 0 versus > 4).; - The linearity of the relation between the relative hazard ratio and the diameter of the tumor, age, and ER level of expression was tested with use of the Wald test for nonlinear components of restricted cubic splines.; - Hazard ratio proportionality was assessed by the method of Grambsch and Therneau.; - Difference between the relative hazard ratio before and after five years of follow-up with respect to the 70-genes prognosis signature was done by the Wald test.
| Results:; - The 70-genes gene expression signature:
| Proved to be associated with age, tumor grade, ER status (P value<0.001), and tumor size (P value=0.012)
| Was not associated with lymph-nodes, vascular invasion, surgery, chemotherapy, hormonal therapy
| - OR for the various subgroups of patients in the consecutive series analyzed:
| 78 node negative patients used in van't Veer 2002^21^
| 31 Poor signature with metastases
| 18 Poor signature without metastases
| 3 Good signature with metastases
| 26 Good signature with out metastases
| OR = 15, (95%CI = 3.3–56, p value < 0.001)
| 67 node-negative patients NOT used in van't Veer 2002:
| 11 Poor signature with metastases
| 23 Poor signature without metastases
| 1 Good signature with metastases
| 32 Good signature with out metastases
| OR = 15.3, (95%CI = 1.8–127, p value = 0.003)
| 180 node-positive and negative patients NOT used in van't Veer 2002:
| 39 Poor signature with metastases
| 65 Poor signature without metastases
| 3 Good signature with metastases
| 73 Good signature with out metastases
| OR = 14.6, (95%CI = 4.3–50, p value < 0.0001)
| - Probability of metastases at 5yrs for all the patients:
| 115 Good signature patients: 94.7±2.1SE
| 180 Poor signature patients: 60.5±3.8SE
| - Probability of metastases at 10 yrs for all the patients
| 115 Good signature patients: 85.2±4.3SE
| 180 Poor signature patients: 50.6±4.5SE
| - Probability of metastases at 5 yrs for node negative patients:
| 93 Good signature patients: 4±3.2SE
| 91 Poor signature patients: 56.2±5.5SE
| - Probability of metastases at 10 yrs for node negative patients:
| 60 Good signature patients: 86.8±4.8SE
| 91 Poor signature patients: 44.1±6.3SE
| - Probability of metastases at 5 yrs for node positive patients
| 55 Good signature patients: 95.2±2.6SE
| 89 Poor signature patients: 66.3±5.2SE
| - Probability of metastases at 10 yrs for node positive patients
| 55 Good signature patients: 82.7±7.8SE
| 89 Poor signature patients: 56.7±6.4SE
| - OS at 5 yrs for all the patients:
| 15 Good patients 97.4±1.5SE
| 180 Poor patients 74.1±3.3SE
| - OS at 10 yrs for all the patients:
| 115 Good patients 94.5±2.6SE
| 180 Poor patients 54.6±4.4SE
| - OS at 5 yrs for node-negative patients:
| 60 Good patients 96.7±2.3SE
| 91 Poor patients 71.5±4.8SE
| - OS at 10 yrs for node-negative patients:
| 60 Good patients 96.7±2.3SE
| 91 Poor patients 49.6±6.1SE
| - OS at 5 yrs for node-positive patients:
| 55 Good patients 98.2±1.8SE
| 89 Poor patients 76.5±4.6SE
| - OS at 10 yrs for node-positive patients:
| 55 Good patients 92.0±4.8SE
| 89 Poor patients 59.5±6.3SE
| - HAZARD RATIO for metastases as first event over the entire follow-up period:
| All patients, HR = 5.1, (95%CI = 2.9–9.0, p value < 0.001)
| 151 node negative patients, HR = 5.5, (95%CI = 2.5–12.2, p value < 0.001)
| 144 mode positive patients, HR = 4.5, (95%CI = 2–10.2, p value < 0.001)
| - HAZARD RATIO for OS over the entire follow-up period:
| All patients = 8.6, (95%CI = 4–19, p value < 0.001)
| - In multivariate analysis the following factors resulted to be independent predictors of risk of metastases as first event within 5 years:
| 70-genes signature, HR = 4.6, 95%CI = 2.3–9.2, p value < 0.001
| Tumor size, HR = 1.56, 95%CI = 1.22–2.0, p value < 0.001
| Chemotherapy, HR = 0.37, 95%CI = 0.2–0.66, p value < 0.001
| The other covariates used (age, grade, node status, vascular invasion, ER status, surgery, and hormonal therapy) were not associated with the risk of metastasis
| - Reclassification and comparison with St. Gallen and NIH criteria:
| The 70-genes signature classified more node negative patients in the Good prognosis group than both the St. Gallen and NIH criteria (40%, 15% and 7% respectively)
| 43 St. Gallen High Risk group patients were re-classified in the Good signature group
| 86 St. Gallen High Risk group patients were classified in the Poor signature group
| KM analysis showed that the 70-genes signature groups defined within the St. Gallen High Risk group are different, with a p value < 0.001
| 17 St. Gallen Low Risk group patients were classified in the Good signature group
| 5 St. Gallen Low Risk group patients were classified in the Poor signature group
| KM analysis showed that the 70-genes signature groups are PROBABLY different within the St. Gallen Low Risk group, with a p value < 0.11
| 53 NIH High Risk patients were classified in the Good signature group
| 87 NIH High Risk patients were classified in the Poor signature group
| KM analysis showed that the 70-genes signature groups are different within the NIH High Risk group, with a p value < 0.001
| 7 NIH-Low Risk group patients were classified in the Good signature group
| 4 NIH-Low Risk group patients were classified in the Poor signature group
| KM analysis showed that the 70-genes signature groups are different within NIH Low Risk group, with a p value < 0.05;
van't Veer, 2002^21^ | Context: 70-genes gene expression signature development using a gene expression array containing 25,000 features was used to select genes associated with metastases free survival at 5 years from the surgery. | The 70-genes signatures is a better predictor of the risk of distant metastases than standard clinical predictors;
| End point: distant metastases as first relapse event; patients were censored on the date of the last follow-up visit, death from causes other than breast cancer, the recurrence of local or regional disease, or the development of a second primary cancer, including contralateral breast cancer.
| Methods:; - Kaplan-Meier analysis on the time form surgery to the first metastasis event or to censoring.; - Survival curves were compared by the log-rank test.; - Multivariate proportional-hazards regression analysis was used to investigate the association between the correlation coefficient and the time to metastases by adjusting for other clinical variables.; - In the multivariate analysis the following predictors were used: tumor grade, ER status, PR status, tumor size, patient age, and angioinvasion.; - Values were expressed as means ±SE, calculated according to the method of Tsiatis.; - All SEs were calculated with use of the sandwich estimator.
| Results:; - Optimized 70-genes signature performance in the training set (78 patients):
| 65/78 correct predictions (patients developed or not metastases within 5 years)
| 13 misclassified patients:
| 5 patients with poor prognosis were classified in the 70-gene Good prognosis group
| 8 patients with good prognosis were classified in the 70-gene Poor prognosis group
| - Optimized 70-genes signature performance in the validation set (19 patients):
| 17/19 correct predictions (patients developed or not metastases within 5 years)
| 2 misclassified patients:
| 1 patients with poor prognosis was classified in the 70-gene Good prognosis group
| 1 patients with good prognosis in the 70-gene Poor prognosis group
| - ODDS RATIO to develop metastases within 5 years for a patient in the 70-genes Poor prognosis group:
| OR=28, (95%CI=7–107), P value = 0.00000001
| Leave-one-out cross-validated OR =15, (95%CI=4–56), P value=0.0000041
| - In univariate analysis the ‘leave-one-out’ cross-validated 70 genes signature proved to be a better predictor of recurrence than grade, size(>2cm), age (<40yrs), ER negative status, and angioinvasion; - In multivariate analysis the 70-genes signature showed to be an independent predictor of metastases within 5 years (logistic regression OR = 18, (95%CI=3.3–94, P value = 0.00014); - Comparison of the 70 genes signatures with St. Gallen and NIH criteria for risk stratification:
| St. Gallen:
| 64/78 patients were defined as at high risk of metastases (33/34 of the patients who did develop metastases; 31/44 who did not develop metastases)
| NIH:
| 72/78 patients were defined as at high risk of metastases (32/34 of the patients who did develop metastases; 40/44 who did not develop metastases)
| 70-genes signature:
| 43/78 patients were defined as at high risk of metastases (31/34 of the patients who did develop metastases; 18/44 who did not develop metastases);

TRANSBIG= Breast International Group (BIG) network for improved treatment tailoring; OS= overall survival; RFS = relapse free survival; TTM = time to distant metastases; ROC= receiver operating characteristic; ER= estrogen receptor; NPI= Nottingham Prognostic Index; CI= confidence interval; RT-PCR= real time polymerase chain reaction; qRT-PCR= quantitative real time polymerase chain reaction; HR= hazard ratio; RNA= ribonucleic acid; OR= odds ratio; SE= standard error; NIH= National Institutes of Health; Kaplan Meier= Kaplan Meier; PR= partial relapse.

Table 10 Evidence Table. Study design, H/I ratio

Study, Year | Country | Study (data collection) period | Study Type | Population size, N | Blinded (Y/N) | Study purpose
Fan, 2006 ^79^ | Netherlands | NR | retrospective | Poor prognosis, 180 | NA | Validation of signature
| | | | Good prognosis, 115
Goetz, 2006 ^62^ | USA | NR | RCT | With expression ratio data, 206 | NR | Validation of signature
| | | | Without expression ratio data, 50
Jansen, 2007 ^72^ | Netherlands | 1979-1996 | retrospective | LN-/ER-, 185 | NR | Validation of signature
| | | | LN-/ER+, 468
| | | | LN+/ER-/NO-, 41
| | | | LN+/ER+/NO-, 151
| | | | LN+/ER uk/YES adjuvant, 407
Jerevall, 2007 ^63^ | Sweden | 1982 - 1995 | retrospective | Post-menopausal, 264 | NR | Validation of signature
Ma, 2004 ^64^ | USA | 1987-1997 | retrospective | Frozen, recurrence, 28 | NR | Validation and development of signature
Ma, 2006 ^61^ | USA | 2001 | prospective | Tomoxifen treated, 286 | NR | Validation and development of assay
| | | | Untreated, 566
| | | | Frozen, non-recurrence, 32
| | | | FFPE, recurrence, 10
| | | | FFPE, non-recurrence, 10
Reid, 2005 ^69^ | USA | NR | prospective | Tamoxifen treated58 | NR | Validation of signature
| | | | Pre-menopausal, 93

NR = not reported; NA = not applicable; LN = lymph node; ER = estrogen receptor, NO = node; uk = unknown; FFPE =formalin fixed paraffin embedded.

Table 11 Evidence Table. Study population characteristics, H/I ratio

Study, Year | Intervention | General Characteristics | Diagnosis (es)* | Treatments and Outcomes
Goetz, 2006 ^62^ | Tamoxifen 20mg/day for 5 years | Age, median (range): 68 (42–84) | H Ductal; 86% | Treatment:
| | Menopausal status: 100 % | H Lobular; 10% | s: Mastectomy; 83%
| | Race (%): W (92) | H Other; 4% | s: Breast Conservation; 17%
| | Exclusion criteria: NR | TS <3; 76% | Outcome NR
| | | TS ≥3; 24%
| | | LN+ nodes 0, 63%
| | | LN+ nodes 1–3, 26%
| | | LN+ nodes 4–9, 7%
| | | LN+ nodes ≥10, 4%
| | | ER 10–49 fmol; 20%
| | | ER ≥50 fmol; 69%
| | | ER +; 11%
| | | HER2 0; 11%
| | | HER2 1; 36%
| | | HER2 2; 34%
| | | HER2 Unknown; <1%
| | | Nottingham TG 1, 26%
| | | Nottingham TG 2, 55%
| | | Nottingham TG 3, 18%
| | | Nottingham TG Unknown, <1%
| | | Diagnostic method: RT-PCR
| Tamoxifen 20mg/day for 5 years (women without expression ratio data-all treated with oral tamoxifen) | Age, median (range): 64 (48–87) | H Not Determined | Treatment:
| | Menopausal status: 100 % | TS <3; 90% | s: Mastectomy; 74%
| | Race (%): W (91) | TS ≥3; 10% | s: Breast Conservation; 26%
| | Exclusion criteria: NR | LN+ nodes 0, 62% | Outcome: NR
| | | LN+ nodes 1–3, 15%
| | | LN+ nodes 4–9, 715
| | | LN+ nodes ≥10, 6%
| | | ER 10–49 fmol; 20%
| | | ER ≥50 fmol; 56%
| | | ER+; 24%
| | | HER2 Not determined
| | | Nottingham TG; Not determined
| | | Diagnostic method: RT-PCR
Jansen, 2007 ^72^ | 1,683 total female patients diagnosed with breast cancer from 1979-1996, clinical information available for 1,252 primary tumor specimens, subgroups (from figure1)^‖^ | Age: NR | Premenopausal: | Treatment received by 406 patientst:
| | Menopausal status: NR | LN+ >3Nodes; 330 (27%) | s: breast-conserving lumpectomy, 543 (43)
| | Race: NR | LN+ 1–3Nodes; 269 (21%) | mastectomy, 709 (57)
| | Exclusion criteria: distant spread at or within the first month of surgery | LN-; 653 (52%) | h: 177 patients (44)
| | | TS <2cm; 392 (31%) | a: 214 (53)
| | | TS 2–5cm; 716 (57%) | c: 15 (3)
| | | TS >5cm/pT4; 144 (12%) | Follow-up:
| | | ER High; 917 (73%) | 72 months, all patients (2–248 months)
| | | ER Low; 335 (27%) | 91 months, 692 patients alive (3 to 248 months)
| | | PR High; 764 (61%) | 46 months, 560 deaths (2 to 205 months)
| | | PR Low; 417 (33%) | Outcome:
| LN-/ER- = 185 (15%) | Age, n (%): < 40, 166 (13) | Diagnostic method: RT-PCR | Disease recurrence occurred in 692 (55%) of 1,252 patients.
| | Menopausal status: pre, n-537 (43%) | note1: The cutoff point to classify primary breast tumors as ER and/or progesterone receptor (PgR) -positive was 10 fmol/mg cytosolic protein. | 846 patients (68%) did not receive neo-adjuvant systemic therapy
| | Race: NR | note2: Follow-up, tumor staging, and response to therapy was defined by standard International Union Against Cancer (Geneva, Switzerland) classification criteria | - 381 patients (45%) experienced a relapse, of which 285 (75%) were treated with hormonal therapy of which;193 patients (68%) received first-line tamoxifen monotherapy, of which: Therapy failure occurred in 73 patients (38%), of which:61 patients (84%) had progressive disease; 12 patients (16%) showed stable disease < 6 months;; - 381 patients (45%) experienced a relapse, 193 patients (68%) received first-line tamoxifen monotherapy, of which: 120 (62%) of these 193 patients experienced a clinical benefit from first-line tamoxifen, of which: disease-free survival (DFS) in patients with primary breast cancer (N = 619) and progression free; survival (PFS) in patients with recurrent breast cancer treated with first-line tamoxifen monotherapy (N = 193).
| | Exclusion criteria: missing values for lymph node status, ER protein status, and HOXB13 and IL17BR
| LN-/ER+ = 468 (37%) | Age, n (%): 40–55,: 465 (37)
| | Menopausal status: post, n=715 (57%)
| | Race: NR
| | Exclusion criteria: 30% epithelial tumor cells in their tumor specimens
| LN+/ER-/LN-adjuvant = 41 (3%) | Age, n (%): 56–70, 409 (33)
| | Menopausal status: NR
| | Race: NR
| | Exclusion criteria: specimens of poor RNA quality
| LN+/ER+/LN-adjuvant = 151 (12%) | Age, n (%): >70, 212 (17)
| | Menopausal status: NR
| | Race: NR
| | Exclusion criteria: NR
| LN+/ER uk/ YES adjuvant = 407 (33%) | Age: NR
| | Menopausal status: NR
| | Race: NR
| | Exclusion criteria: NR
Jerevall, 2007 ^63^ | Postmenopausal patients: randomized clinical trial, comparing 2 years (163 patients, 62%) and 5 years (101 patients, 38%) of adjuvant tamoxifen treatment | Age: NR | Postmenopausal: | Treatment:
| Premenopausal patients: clinical trial comparing tamoxifen treatment versus no treatment, only untreated patients were used | Menopausal status: NR | LN+; 73 (28%) | s: Modified radical mastectomy
| | Race: NR | LN-; 184 (72%) | s: breast conserving surgery with axillary lymph node dissection;
| | Exclusion criteria: NR | LN Unknown; 7 (?%) | radiotherapy (50 Gy/25 fractions) to lymph node-positive patients;
| | | TS <2cm; 77 (29%)
| | | TS ≥2cm; 187 (71%)
| | | ER +; 195 (74%)
| | | ER -; 69 (26%)
| | | PR +; 142 (54%)
| | | PR -; 120 (46%)
| | | Premenopausal:
| | | LN+; 63 (28%)
| | | LN-; 67 (72%)
| | | TS <2cm; 24 (26%)
| | | TS ≥2cm; 69 (74%)
| | | ER +; 59 (63%)
| | | ER -; 34 (37%)
| | | PR +; 60 (65%)
| | | PR -; 33 (35%)
| | | Nottingham TG 4, 4 (4.9%)
| | | Nottingham TG 2, 38 (47%)
| | | Nottingham TG 3, 39 (48%)
| | | Nottingham TG Unknown, 12 (?%)
| | | Diagnostic method: RT-PCR
Ma, 2004 ^64^ | Frozen, recurrence, n=28 | Age, mean y (range): 65.1 (48–84) | TS mean, 2.7 | Treatment: NR
| | Menopausal status: NR | TS range, 0.9–4.7 | Outcome:
| | Race: NR | LN# 0, 13 | DFS: mean months (range): 54.8 (5–137)
| | Exclusion criteria: NR | LN# 1–3, 6
| | | LN# >3, 6
| | | TG 1, 2
| | | TG 2, 15
| | | TG 3, 11
| | | ER+, 27
| | | PR+, 23
| | | Diagnostic method: microarray and RT-PCR
| Frozen, non recurrence, n=32 | Age, mean y (range): 69.1 (54–85) | TS mean, 2.1 | Treatment: NR
| | Menopausal status: NR | TS range, 0.8–5.5 | Outcome:
| | Race: NR | LN# 0, 15 | DFS: mean months (range): 115.6 (61–169)
| | Exclusion criteria: NR | LN# 1–3, 11
| | | LN# >3,2
| | | TG 1, 1
| | | TG 2, 24
| | | TG3, 7
| | | ER+, 32
| | | PR+, 27
| | | Diagnostic method: microarray and RT-PCR
| Formalin-fixed paraffin embedded (FFPE), recurrence, n=10 | Age, mean y (range): 65.5 (54–93) | TS mean, 1.9 | Treatment: NR
| | Menopausal status: NR | TS range, 1.1–4 | Outcome:
| | Race: NR | LN# 0, 8 | DFS: mean months (range): 51.4 (15–117)
| | Exclusion criteria: NR | LN# 1–3,1
| | | LN# >3, 0
| | | TG 1, 1
| | | TG 2, 6
| | | TG3, 3
| | | ER+, 10
| | | PR+, 8
| | | Diagnostic method: RT-PCR
| FFPE, non recurrence, n=10 | Age, mean y (range): 65.2 (57–74) | TS mean, 1.7 | Treatment: NR
| | Menopausal status: NR | TS range, 0.8–4 | Outcome:
| | Race: NR | LN# 0, 10 | DFS: mean months (range): 95.8 (25–123)
| | Exclusion criteria: NR | LN# 1–3, 0
| | | LN# >3, 0
| | | TG 1, 1
| | | TG 2, 8
| | | TG3, 1
| | | ER+, 10
| | | PR+, 10
| | | Diagnostic method: RT-PCR
Ma, 2006 ^61^ | All samples, n=852 | Age, n (%): | TS<2, 309 (36) | Treatment:
| | <50, 155 (18) | TS 2–5, 460 (54) | a: With or without adjuvant tamoxifen monotherapy
| | >50, 695 (82) | TS >5, 75 (9) | s: Mastectomy or lumpectomy plus axillary dissection
| | UK, 2 (0.2) | TS UK, 8 (1) | r: With or without postoperative radiation therapy
| | Menopausal status: NR | LN# =0, 613 (72) | Outcome:
| | Race: NR | LN#=1–3, 134 (16) | RFS: mean =70 (0–285)
| | Exclusion criteria: NR | LN#=4+, 105 (12) | RS: 266 (31)
| | | ER+, 625 (73) | D: cancer: 206 (24)
| | | ER-, 214 (25) | D: other: 155 (18)
| | | ER UK, 13 (2)
| | | HER2-CISH 0–3, 589 (69)
| | | HER2-CISH 4–12, 133 (16)
| | | HER2-CISH UK, 130 (15)
| | | PR+, 461 (54)
| | | PR-, 382 (45)
| | | PR UK, 9 (1)
| | | SP<6, 215 (25)
| | | SP 6–10, 213 (25)
| | | SP>10, 287 (34)
| | | SP UK, 137 (16)
| | | PL dip, 281 (33)
| | | Pl An, 465 (55)
| | | Pl UK, 106 (12)
| Tamoxifen treated, n=286 | Age, n (%): | TS<2, 102 (36) | Treatment:
| | <50, 26 (9) | TS 2–5, 157 (55) | a: With or without adjuvant tamoxifen monotherapy
| | >50, 260 (91) | TS >5, 26 (9) | s: Mastectomy or lumpectomy plus axillary dissection
| | UK, 0 | TS UK, 1 (0.1) | r: With or without postoperative radiation therapy
| | Menopausal status: NR | LN# =0, 138 (40) | Outcome:
| | Race: NR | LN#=1–3, 79 (28) | RFS: mean =68 (0–231)
| | Exclusion criteria: NR | LN#=4+, 69 (24) | RS: 83 (29)
| | | ER+, 255 (89) | D: cancer: 69 (24)
| | | ER-, 29 (10) | D: other: 49 (17)
| | | ER UK, 2 (1)
| | | HER2-CISH 0–3, 204 (71)
| | | HER2-CISH 4–12, 42 (15)
| | | HER2-CISH UK, 40 (14)
| | | PR+, 188 (66)
| | | PR-, 97 (34)
| | | PR UK, 1 (0.1)
| | | SP<6, 69 (24)
| | | SP 6–10, 89 (31)
| | | SP>10, 89 (31)
| | | SP UK, 39 (14)
| | | PL dip, 95 (33)
| | | Pl An, 166 (58)
| | | Pl UK, 25 (9)
| | | Diagnostic method: RT-PCR
| Untreated, n=566 | Age, n (%): | TS<2, 207 (37) | Treatment:
| | <50, 129 (23) | TS 2–5, 303 (54) | a: With or without adjuvant tamoxifen monotherapy
| | >50, 435 (77) | TS >5, 49 (9) | s: Mastectomy or lumpectomy plus axillary dissection
| | UK, 2 (0.2) | TS UK, 7 (1) | r: With or without postoperative radiation therapy
| | Menopausal status: NR | LN# =0, 475 (84) | Outcome:
| | Race: NR | LN#=1–3, 66 (10) | RFS: mean =71 (0–285)
| | Exclusion criteria: NR | LN#=4+, 36 (6) | RS: 183 (32)
| | | ER+, 370 (65) | D: cancer: 137 (24)
| | | ER-, 185 (33) | D: other: 106 (17)
| | | ER UK, 11 (2)
| | | HER2-CISH 0–3, 385 (68)
| | | HER2-CISH 4–12, 91 (16)
| | | HER2-CISH UK, 90 (16)
| | | PR+, 273 (48)
| | | PR-, 285 (50)
| | | PR UK, 8 (1)
| | | SP<6, 146 (26)
| | | SP 6–10, 124 (22)
| | | SP>10, 198 (35)
| | | SP UK, 98 (17)
| | | PL dip, 186 (33)
| | | Pl An, 299 (53)
| | | Pl UK, 81 (14)
| | | Diagnostic method: RT-PCR
Reid, 2005 ^69^ | 58 patients treated with Tamoxifen 20mg/day for 5 years | Age, n (%): | H Ductal; 48/58 (83.0%) | Treatment: NR
| | ≥50yrs, 4 (6.9) | H Lobular; 6/58 (10.2%) | Outcome: NR
| | >50yrs, 54 (93.1) | H Ductal + Lobular; 2/58 (3.4%)
| | Menopausal status: NR | H Other; 2/58 (3.4%)
| | Race: NR | TS ≤2cm; 22/58 (37.9%)
| | Exclusion criteria: NR | TS >2cm; 36/58 (62.1%)
| | | LN# 0; 13/58 (22.5%)
| | | LN# 1–3; 31/58 (53.5%)
| | | LN# ≥4; 14/58 (24.0%)
| | | TG 1; 3/58 (5.0%)
| | | TG 2; 28/58 (48.3%)
| | | TG 3; 12/58 (20.7%)
| | | TG Not Assessed; 15/58 (26.0%)HER2 -; 46/58 (77.6%)
| | | HER2 +; 12/58 (20.7%)
| | | PR -; 12/58 (20.7%)
| | | PR +; 46/58 (79.3%)
| | | Diagnostic method: RT-PCR

* Diagnoses: H = histology/histologic type; TS = tumor size/diameter; LN# = # of Lymph nodes at primary diagnosis; LN = lymph node status; TG = tumor grade; ER = estrogen receptor status; HER = HER neu status; PR = Progesterone receptor status; SP = S-phase fraction; Pl = ploidy; VI = vascular invasion; PTS = site of primary tumor; HR = hormonal status, ER or PR or both; DR = distant recurrence

† Treatments: H = hormonal; A = adjuvant; S = surgical; R = radiation; c = combination

‡ Treatment outcomes: OS = overall survival; RFS = relapse-free survival (first disease relapse, irrespective of site); CR = complete response; PR = partial response; RS: recurrence score; SD = stable disease; PD = progressive disease; PCR = pathologic complete response; D = death

§ Data not reported in article, referred directly to van de Vijver, 2002^25^.

‖ all patients were analyzed, however the following groups are of relevance: (LN-/ER+) and (LN+/ER+/NO-adjuvant); and 116 from (LN-/ER+) and 77 from (LN+/ER+/NO-adjuvant), total of 193 (15%), who received first-line tamoxifen treatment

NR= not reported; RT-PCR= reverse transcriptase polymerase chain reaction; DFS= disease free survival; FFPE= formalin-fixed paraffin embedded

Table 12 Evidence Table. Analytic validity, H/I ratio

Study, year | Measure | Conclusions
Goetz, 2006^62^ | Context: Validation of the H/I ratio signature using patients from the randomized NCCTG 89-30-52 trial on tamoxifen treatment. Out of the 256 eligible patients, FFPE were available for 227 patents
| Methods:
| - LMC was performed prior total RNA preparation; - RT-PCR expression values for each gene were normalized using a standard curve obtained analyzing the human universal total RNA (Stratagen, La Jolla, CA); - No reference genes were used
| Results:
| - 206 patients out of 256 successfully analyzed, for the following reasons:
| No specimen available: 29/256 patients (11%)
| Tumor content sufficient: 211/227 patients (93%)
| Failed RT-PCR: 5/211 patients (2.4%)
| Successful assays: 206/211 patients (97.6%)
Jansen, 2007^72^ | Context: Validation of the H/I ratio signature by measuring expression levels normalized to a different set of control genes respect to MA et al 2006^61^ using fresh frozen samples. From a population of 1693, 1,252 were considered eligible and were successfully evaluated
| Methods:
| - RT-PCR was use to measure the expression levels of HOXB13 and IL17BR; - Two pairs of primers-probes were used to evaluated the IL17BR gene, aligning to the 3′ and the 5′ end of the genes and corresponding to the region of the transcripts respectively assayed by Ma et al 2004^64^ and Reid et al 2005^69^; - Three reference genes different from those used by Ma et 2006^61^ were used (porphobilinogen deaminase, hypoxanthine-guanine phospho-ribosyltransferase, and beta-2-microglobulin)
| Results:
| In this study analytic validity data were not reported
Jerevall, 2007^63^ | Context: Validation of the H/I ratio signature. Expression levels were normalized to b-actin using fresh frozen samples. Patients were collected from two distinct institutions; of 373 tumor samples analyzed, RNA expression data were obtained from 357 tumors
| Methods:
| - RT-PCR reactions in the two institutions were performed using the same sets of primers/probes and two distinct instruments; - In each reaction serial dilutions of a standard sample were used to construct a standard curve used to quantify gene expression prior normalization; - The reproducibility between the two institution was assessed by Pearson's correlation
| Results:
| - 357 patients out of 373 successfully analyzed, for the following reasons:
| Insufficient RNA yield: 16/373 patients (4.3%)
| Overall success rate: 357/373 patients (95.7%%)
| - Reproducibility between institutions, Pearson's correlations, 10 patients:
| HOXB13:b-actin, r = 0.96, P < 0.001
| IL17BR:b-actin, r = 0.87, P = 0.002
| HOXB13:IL17BR, r = P < 0.001
| - Median values for all the samples analyzed at the two centers:
| HOXB13:b-actin, 0.086 vs. 0.081
| IL17BR:b-actin, 1.4 vs. 1.3)
| HOXB13:IL17BR, 0.074 vs. 0.055
Ma, 2004^64^ | Context: This study used the H/I ratio signature for the development and preliminary validation of the of the two-gene ratio signature. The training set was analyzed by microarray (n=60) and by RT-PCR (n=59)
| Methods:
| - Comparison of microarray based and RT-PCR based ratio by Pearson's correlation on 59/60 patients
| Results:
| - Correlations between array and RT-PCR:
| HOXB13, r = 0.83
| IL17BR, r = 0.93
| HOXB13/IL17BR, r = 0.83
Ma, 2006^61^ | Context: Development of the HOXB13:IL17BR two-gene index. Out of the 1,002 eligible The FFPE tissue microarrays were 4 years old, and obtained from specimens originally stored as fresh frozen tissues | According to the authors these results confirmed the significant correlations between mRNA and protein levels for ER and PR and provided validation of the FFPE gene expression assay platform.
| Methods:
| - IHC for ER and PR was performed^90,91^; - IHC Allred^92^ scores of 3 to 8 were considered positive for ER or PR^93^; - Concordance between RT-PCR and IHC results by k statistics; - Since both ER and PR mRNA RT-PCR measurements were bimodal; the following midpoints were used as cutoffs:
| 2.5 CT for ER
| 5.9 for PR
| Results:
| - The quality of these tissue microarrays FFPE specimens was comparable with those without the intervening snap-freeze step (data not shown); - 852 patients out of 1002 successfully analyzed, for the following reasons:
| Tumor content < 10%: 132/1002 patients (13.2%)
| Poor RNA yield: 18/870 patients (2%)
| Successful assays: 852/870 (98%)
| - Agreement between IHC vs RT-PCR:
| ER, 91% concordance, k = 0.83, P value = .0001
| PR, 85% concordance, k = 0.70, P value = .0001

NCCTG= North Central Cancer Treatment Group; FFPE = formalin fixed paraffin embedded; LMC= laser micro-dissection; RNA= ribonucleic acid; RT-PCR = reverse transcriptase polymerase chain reaction; IHC = immunohistochemistry; ER = estrogen receptor; PR = progesterone receptor; mRNA= messenger ribonucleic acid.

Table 13 Evidence Table. Clinical utility and validity, H/I ratio

Study, year | Measure | Conclusions
Fan, 2006^79^ | Context: The study is a comparison of classification agreement among 5 different gene expression based predictors (70-genes, Oncotype DX, Wound-response, Intrinsic subtypes and two-gene ratio) using the 295 samples from the consecutive cohort originally used by van de Vijver 2002[reference]. | Good but not perfect correlation between predictions, albeit surprising with different gene sets. Degree of prediction over and above “standard” clinical stratifiers is not clear - reclassification not done.
| Methods:
| - Cramer V statistics; - Kaplan-Meier survival analysis; - Multivariate Cox proportional hazards analysis, adjusting for age, tumor size, tumor grade, ER status, number of lymph node involved; - All analyses were performed using all the patients, as well as the ER positive patients subset (N=225); - NB: coefficients of clinical predictors were allowed to vary between models
| Results:
| - In multivariate Cox proportional hazards analysis all tests except the two-gene ratio were highly significant predictors of OS and DFS:
| 70 genes DFS HR = 3.4 (95%CI = 2.0–6.0), P value < 0.001
| Two-gene ratio DFS HR = 0.91 (95%CI = 0.6–1.3), P value = 0.62
| Oncotype OS HR = 4.3 (95%CI = 2.1–8.9), P value < 0.001
| 70 genes OS HR = 4.71 (95%CI = 2.02–11.0), P value < 0.001
| Two-gene ratio OS HR = 1.00 (95%CI = 0.61–1.63), P value = 0.99
| Oncotype DFS HR = 6.14 (95%CI = 1.84–20.4), P value = 0.003
| - ER status, tumor grade, tumor size, and lymph nodes were also significant predictors.; - Patients classification into dichotomized risks groups proved to be roughly similar, ranging from ~80% to ~40%:
| 70-genes and RS yielded a V= 0.60
| 70-genes and RS yielded an agreement of ~81% (239/295)
Goetz, 2006^62^ | Context: Validation of the H/I ratio signature using patients from a randomized trial on tamoxifen treatment. | A high 2-gene expression ratio is associated with increased relapse and death in patients with node-negative ER positive breast cancer treated with tamoxifen.
| End points:
| - RFS (time from randomization to any event of recurrence, or contralateral breast cancer or death), DFS (time from randomization to any event of recurrence, or contralateral breast cancer, or other cancer, or death), and OS (time from randomization to death); - RT-PCR expression values for each gene were normalized using a standard curve obtained analyzing the human universal total RNA (Stratagen, La Jolla, CA); No reference genes were used; - Specific cut-off points were obtained in the selected population analyzed: none negative (n=130) and node-positive (n=86) patients
| Methods:
| - Cut-off points estimation for the HOXB13:IL-17BR ratio were obtained by minimizing the P value in log-rank tests; - Multiple testing corrected P values from the log-rank test were obtained by the Lausen and Schumacher method, modify by Altman; - Log-rank test and univariate Cox proportional hazard models were used to assess whether distributions of RFS, DFS, or OS differed with respect to the following clinical factors: age, extent of surgery, ER status, number of positive nodes, tumor size, Nottingham grade, HER2 status, prior exposure to estrogens; - Cross-validated HR in Cox proportional hazard models were obtained by the Faraggi-Simon method; - Multivariate Cox proportional hazard models and the likelihood-ration test were applied to asses the contribution of the dichotomized ratio to the model; - In multivariate analysis tumor size, nodal status, tumor grade were included in model
| Results:
| - Nodal status, tumor size and Nottingham grade significantly associated with endpoints; - All patient in the study:
| RFS, Univariate Cox 1.90 (CI 95% 1.25, 2.90)
| RFS, Univariate F-S 1.62 (CI 95% 1.06, 2.48)
| RFS, Multivariate Cox 1.65 (CI 95% 1.06, 2.57)
| RFS, Multivariate F-S 1.45 (CI 95% 0.93, 2.27)
| DFS, Univariate Cox 2.01 (1.36, 2.96)
| DFS, Univariate F-S 1.69 (1.14, 2.51)
| DFS, Multivariate Cox 1.77 (1.17, 2.66)
| DFS, Multivariate F-S 1.57 (1.04, 2.38)
| OS, Univariate Cox 1.95 (1.25, 3.07)
| OS, Univariate F-S 1.55 (0.98, 2.45)
| OS, Multivariate Cox 1.66 (1.04, 2.66)
| OS, Multivariate F-S 1.29 (0.81, 2.08)
| - Node negative patients in the study (n=130):
| RFS, Univariate Cox 2.22 (1.22, 4.05)
| RFS, Univariate F-S 1.99 (1.09, 3.63)
| RFS, Multivariate Cox 1.98 (1.07, 3.68)
| RFS, Multivariate F-S 1.73 (0.92, 3.25)
| DFS, Univariate Cox 2.41 (1.39, 4.18)
| DFS, Univariate F-S 2.12 (1.22, 3.68)
| DFS, Multivariate Cox 2.03 (1.15, 3.59)
| DFS, Multivariate F-S 1.77 (0.99, 3.16)
| OS, Univariate Cox 2.90 (1.47, 5.72)
| OS, Univariate F-S 2.35 (1.21, 4.58)
| OS, Multivariate Cox 2.40 (1.19, 4.84)
| OS, Multivariate F-S 2.01 (1.02, 3.99)
Jansen, 2007^72^ | Context: Validation of the H/I signature by measuring expression levels normalized to a different set of control genes respect to Ma et al 2006.^61^ | High HOXB13-to-IL17BR ratio expression levels associate with both tumor aggressiveness and tamoxifen therapy failure.
| Aims: to evaluate if the HOXB13-to-IL17BR expression ratio predicts response to tamoxifen, and/or cancer intrinsic aggressiveness | The ratio was significantly associated with DFS and PFS in the specific subsets of patients.
| End points: disease-free survival (DFS), progression free survival (PFS), post-relapse survival (PRS), and overall survival (OS); | In multivariate analysis, the ratio was associated with a shorter DFS for node-negative patients only.
| - Subsets of patients used from the total population (n=1252) for specific end points:
| DFS ER+, node negative primary breast cancer, no adjuvant therapy (N = 468);
| PFS in ER+ primary breast cancer, whose recurrence was treated with first-line tamoxifen (N = 193)
| Methods:
| - Two-gene ratio as dichotomized or continuous variable; - Non-parametric methods:
| Spearman rank correlations for ER status, PR status, age;
| Kruskal - Wallis exact test for grade, size, LN status;
| Mann-Whitney U test for menopausal status;
| - Univariate and multivariate Cox regression analysis to compute the hazard ratio; - In multivariate analysis the model for OS and DFS included age, menopausal status, tumor size, lymph node status, grade, and log ER and log PgR mRNA levels; - The model for PRS and PFS included age, menopausal status, DFS, site of relapse, and log ER and log PgR mRNA levels
| Results:
| - All 1252 patients, associations with clinical factors, HOXB13:
| Grade, P < 0.001
| ER status, P < 0.001
| PR status, P < 0.001
| - All 1252 patients, associations with clinical factors, I17RB (both 3′ and 5′):
| Age, P < 0.001;
| Menopausal status, P < 0.005 and P < 0.026
| Tumor size P < 0.035 and P < 0.098
| LN status, P < 0.001
| Grade, P < 0.001
| ER status, P < 0.001
| PR status, P < 0.001
| - Multivariate analysis, ER+, node negative, no adjuvant therapy (N = 468):
| Continuous ratio with 3′ I17RB, DFS HR = 1.04; 95% CI = 1.01 to 1.08; P = 0.015
| Continuous ratio with 5′ I17RB, DFS HR = 1.05; 95% CI = 1.02 to 1.08; P = 0.004
| Dichotomized ratio with 3′ I17RB, DFS HR = 1.74; 95% CI = 1.17 to 2.59; P = 0.006
| Dichotomized ratio with 5′ I17RB, DFS HR = 1.61; 95% CI = 1.08 to 2.41; P = 0.019
| - Multivariate analysis, relapsing ER+, tamoxifen treated (N = 193):
| Continuous ratio with 3′ I17RB, PFS HR = 1.07; 95% CI = 1.04 to 1.11; P < 0.001
| Continuous ratio with 5′ I17RB, PFS HR = 1.05; 95% CI = 1.02 to 1.08; P = 0.004
| Optimal dichotomized ratio with 3′ I17RB, PFS HR = 2.97; 95% CI = 1.82 to 4.86; P < 0.001;
| Standard dichotomized ratio with 3′ I17RB, PFS HR = 1.95; 95% CI = 1.39 to 2.73; P < 0.001;
| Optimal dichotomized ratio with 5′ I17RB, DFS HR = 3.31; 95% CI = 2.05 to 5.34; P < 0.001;
| Standard dichotomized ratio with 5′ I17RB, DFS HR = 2.12; 95% CI = 1.52 to 2.97; P < 0.001;
Jerevall, 2007^63^ | Context: Validation of the H/I ratio signature. Expression levels were normalized to b-actin. | The ratio or HOXB13 alone can predict the benefit of endocrine therapy, with a high ratio or a high expression rendering patients less likely to respond.
| Aims: to evaluate if the HOXB13-to-IL17BR expression ratio can predict the benefit of 5 years versus 2 years of tamoxifen treatment of postmenopausal patients; | Lower expression of IL17BR, but not HOXB13, was correlated to several factors related to poor prognosis, IL17BR might be an independent prognostic factor in breast cancer.
| End points: Recurrence-free survival (RFS), defined as the time from diagnosis to local, regional, or distant recurrence or death due to breast cancer; OS, defined as the time elapsed from diagnosis to the date of death due to breast cancer;
| Methods:
| - The relationships between grouped variables were analyzed with the chi-squared test, or the chi-squared test for trend when required;; - Spearman's rank order correlation was used when comparing HOXB13 and IL17BR levels;; - Survival curves were calculated using the Kaplan-Meier method and analyzed with the log rank test.; - Multivariate analysis of recurrence and mortality rates was performed with Cox proportional hazard model;; - A Cox model was also used to test for the interaction between the two-gene ratio and the benefit from prolonged duration of tamoxifen treatment;; - The following variables were included: HOXB13:IL17BR, treatment (5 vs. 2 years), lymph node status (N+ vs. N-), tumor size ( > 20 mm vs. > 20 mm), PgR status (PgR+ vs. PgR), and an interaction variable (HOXB13:IL17BR × treatment);
| Results:
| - The ratio is significantly correlated to:
| tumor size, P = 0.003
| ER, P < 0.001
| PR, P < 0.001
| HER2, P = 0.003
| NHG, P < 0.001
| Ploidy, P < 0.001
| S-phase, P = 0.005
| ER, HER2, S-phase and NHG correlations are mostly due to IL17BT
| PR and ploidy correlation have contribution from both genes
| - Post-menopausal ER+ patients, low ratio was associated with a benefit from a prolonged tamoxifen treatment (P = 0.021; in KM analysis for RFS), mainly due to the low expression of HOXB13 genes (P = 0.010, in KM analysis for RFS); - Postmenopausal ER+ patients (n=179), multivariate Cox proportional hazard model analysis:
| Recurrence Rate (5y vs 2y), low ratio: 0.39 (CI 95% = 0.17–0.91), P value = 0.030
| Test for interaction: P value = 0.035
| Recurrence Rate (5y vs 2y), HOXB13: 0.37 (CI 95% = 0.17–0.83), P value = 0.015
| Test for interaction: P value = 0.018
| - Postmenopausal ER+, node negative, patients (n=134), multivariate Cox proportional hazard model analysis:
| Recurrence Rate (5y vs 2y), low ratio: 0.27 (CI 95% = 0.10–0.72), P value = 0.0087
| Test for interaction: P value = 0.014
| Recurrence Rate (5y vs 2y), HOXB13: 0.30 (CI 95% = 0.12–0.73), P value = 0.0083
| Test for interaction: P value = 0.0081
Ma, 2004^64^ | Context: This study used the two-gene ratio signature for the development and preliminary validation of the of the two-gene ratio signature prognostic value in patients with early stage breast cancer treated with tamoxifen. The training set was analyzed by microarray (n=60) and by RT-PCR (n=59); the validation set (n=20) was evaluated by RT-PCR (3′ probes used) | 2-gene ratio predicts tumor recurrence in the setting of tamoxifen therapy.
| End points: DFS was calculated from the date of diagnosis.
| Methods:
| - Two-sample t test;; - Receiver Operating Characteristic (ROC) analysis; Statistical test of significance of ROC curves by the DeLong method; - Univariate and multivariate logistic regression; All predictors (tumor size, PGR, ERBB2, 2 gene-ratio) used as continuous variables; - Kaplan-Meier survival analysis and log-rank test
| Results:
| - Microarray data, training set, two-genes ratio, Univariate logistic regression:
| OR = 10.17 (95% CI 2.9–35.6, p Value = 0.0003)
| - Microarray data, training set, two-genes ratio, Multivariate logistic regression:
| OR = 7.3 (95% CI 2.1–26.3, p Value = 0.002
| This outperforms the other variables
| - Classification results in the validation set (RT-PCR data):
| 16/20 correctly classified
| Correct prediction probability = 0.01 (95% CI = 56%–94%), by exact binomial test;
| 9/10 disease free patients correctly classified
| 7/10 relapse patients correctly classified
| - Kaplan-Meier survival analysis, log-rank test, RT-PCR on the training set: P value = 0.0000058; - Kaplan-Meier survival analysis, log-rank test, RT-PCR on the validation set: P value = 0.002
Ma, 2006^61^ | Context: Development of the HOXB13:IL17BR two-gene index, through validation of the HOXB13:IL17BR two-gene ratio signature. | The HOXB13:IL17BR index was only significant in node-negative patients.
| Aim: to evaluate if the two-gene expression index (HOXB13:IL17BR) could predict outcome in patients treated and untreated with tamoxifen monotherapy | Higher HOXB13:IL17BR index was associated with a higher risk of relapse.
| End points: Relapse-free survival (RFS), defined as the time from initial diagnosis to any recurrence. Optimal threshold for dichotomization was identified and applied in the analysis | Two-gene index was a significant predictor of clinical outcome in ER+, node-negative, patients irrespective of tamoxifen therapy.
| Methods:
| - Spearman rank correlation was used to assess association between the HOXB13:IL17BR index and the other prognostic factors; - Cox proportional hazards regression and Kaplan-Meier analyses were used to examine the associations between gene expression indices and RFS; - Using untreated patients, cut-point selection was tuned to obtained the smallest log-rank P value using values between the 10th and 90th percentile; Cut-point selection was obtained from a training set and validated on a test set; Such cut-off was then used in treated patients
| Results:
| - Interaction of HOXB13:IL17BR index with other clinical factors in ER+ patients:
| Node status, r = 0.13, P value = 0.0015
| HER2, r = 0.17, P value < 0.0001
| S-phase, r = 0.15, P value = 0.0004
| ER, r = -0.23, P value < 0.0001
| PR, r = -0.26, P value < 0.0001
| - Univariate Cox regression analysis:
| All patients (n=852), Interquartile HOXB13:IL17BR HR = 1.47 p = 9e-06
| Node positive (n = 239), Interquartile HOXB13:IL17BR HR = 1.19 p = 0.1
| Node negative (n = 613), Interquartile HOXB13:IL17BR HR = 1.64, p = 2e-05
| - Kaplan-Meier survival analysis results, ER+, node negative patients:
| Untreated patients, Test set (n=103), P value 0.0012
| Treated patients, (n=122), P value =0.026
| - Multivariate Cox Regression Analysis; ER+ node negative, untreated test set and tamoxifen treated patients (n = 225), dichotomized HOXB13:IL17BR index (high versus low):
| HR = 3.9 (95% CI = 1.5 to 10.3) p value = 0.007
| - Two-gene index on a continuous scale, 5-year recurrence risk for untreated patients:
| Index of -2.0 = 15% (95% CI, 9.8% to 20.5%)
| Index of +2.0 = 36% (95% CI, 26.5% to 45.2%)
Reid, 2005^69^ | Context: Validation of the H/I ratio signature using an independent cohort of 58 ER+ patients treated with tamoxifen. Re-analysis of the original microarray data and of an independent data set | Although the proposed predictive model is very appealing the use of the two-gene ratio signature in an independent population yielded statistically non-significant results.
| End points: DFS | The authors failed to confirm he association of the ratio with response to tamoxifen on their cohort (which is however different in terms of clinical characteristics from the original Ma, 2004^64^ cohort). The authors also failed to classify patients using Discriminant Linear Analysis on two published data sets, including the Ma, 2004^64^ original series.
| Methods:
| - RT-PCR measurement of HOXB13 and IL17BR gene expression (5′ probes used); - Univariate logistic regression; - Area Under the receiver-operating-Characteristic curve (AUC); - Two-sample t test and Mann-Whitney test
| Results:
| - Univariate logistic regression: odds ratio:
| HOXB13 OR = 1.04, 95% CI = 0.92 to 1.16, P = 0.54
| IL17BR OR = 0.69, 95% CI = 0.40 to 1.20, P = 0.18
| HOXB13/IL17BR OR = 1.30, 95% CI = 0.88 to 1.93, P = 0.18
| - Similar results by the other methods; - About Ma 2004 validation data:
| 9/10 disease free patients were correctly classified; Correct prediction probability 0.02 (95% CI = 52%–99%)
| 7/10 relapse patients correctly classified; Correct prediction probability = 0.34 (95% CI = 35%–93%)

ER = estrogen receptor; OS = overall survival; DFS= disease free survival; HR= hazard ratio; CI= confidence interval; RFS = recurrence free survival; RT-PCR= reverse transcriptase polymerase chain reaction; RNA= ribonucleic acid; HER-2 = human epidermal growth factor receptor 2; PFS = progression LN = lymph node; mRNA= messenger ribonucleic acid; NHG= Nottingham histologic grade; ROC= receiver operating characteristic; PGR= progesterone receptor gene; AUC= area under the receiver operating characteristic curve