# Appendix F: Detailed Electronic Database Search Strategies

## MEDLINE Strategy

(((“breast neoplasms”[mh] OR “breast cancer”[tiab] OR (breast[tiab] AND neoplasm[tiab])) AND ((Gene[tiab] AND expression[tiab]) OR “gene expression profiling”[mh] OR “gene expression”[mh]) AND 1990 : 2007[dp] AND Eng[lang]) NOT((animals[mh]NOT humans[mh]) OR review[pt])) NOT Tumor Cells, Cultured[mh] | 3356

## Cochrane Library (Reviews and CENTRAL) Strategy

([underlined: “breast neoplasms” or “breast cancer”:ti,ab,kw or (breast AND cancer):ti,ab,kw or (breast AND neoplasm):ti,ab,kw]) AND ([underlined: “gene expression profiling” or “gene expression” or “gene expression” AND profiling:ti,ab,kw or “gene expression” AND (test OR tesing):ab]) | 55

## EMBASE Strategy

((((‘breast tumor’/exp) OR (breast:ti,ab AND cancer:ti,ab)) AND (((‘gene expression’/exp) OR (‘gene expression profiling’/exp)) OR (‘gene expression’:ab,ti AND profiling:ab,ti))) NOT ((‘cell culture’/exp) OR (‘validation study’/exp) OR (apoptosis:ab,ti) OR (‘cell death’:ab,ti) OR (transcriptional:ti,ab AND mechanism:ti,ab) OR (transcriptional:ti,ab AND machinery:ti,ab)) AND [english]/lim AND [humans]/lim AND [1990-2007]/py) NOT (review:it) | 7531

## CINAHL

((MH “breast neoplasms” or TX “breast cancer” ) OR (TX ( Breast AND cancer ) or TX ( breast AND neoplasm ))) AND (TX “gene expression profiling” or TX ( “gene expression” AND profiling ) or TX ( gene AND profiling ) ) | 73

## MEDLINE (targeted authors search)

(((van't veer LJ[au] OR Dai H[au] OR van de vijver MJ[au] OR He YD[au] OR Hart AM[au] OR Hart AA[au] OR Mao M[au] OR Peterse HL[au] OR van der kooy K[au] OR Marton MJ[au] OR Witteveen AT[au] OR Schreiber GJ[au] OR Kerkhoven RM[au] OR Roberts C[au] OR Linsley PS[au] OR Bernards R[au] OR Friend SH[au] OR Voskuil DW[au] OR Parrish M[au] OR Atsma D[au] OR Witteveen A[au] OR Glas A[au] OR Delahaye L[au] OR van der velde T[au] OR Bartelink H[au] OR Rodenhuis S[au] OR Rutgers ET[au]) OR (paik S[au] OR shak S[au] OR Tang G[au] OR Kim C[au] OR Baker J[au] OR Cronin M[au] OR baehner FL[au] OR walker MG[au] OR Watson D[au] OR Park T[au] OR Hiller W[au] OR Fisher ER[au] OR Wickerham DL[au] OR Bryant J[au] OR Wolmark N[au]) OR (Ma XJ[au] OR Wang Z[au] OR Ryan PD[au] OR Isakoff SJ[au] OR Barmettler A[au] OR Fuller A[au] OR Muir B[au] OR Mohapatra G[au] OR Salunga R[au] OR Tuggle JT[au] OR Tran Y[au] OR tran D[au] OR Tassin A[au] OR Amon P[au] OR Wang W[au] OR Enright E[au] OR Stecker K[au] OR Estepa-Sabal E[au] OR Smith B[au] OR Younger J[au] OR Balis U[au] OR Michaelson J[au] OR bhan A[au] OR Habin K[au] OR Baer TM[au] OR Brugge J[au] OR Haber AH[au] OR Erlander MG[au] OR Sgroi DC[au])) AND gene[tw]) AND (((Gene[tiab] AND expression[tiab]) OR “gene expression profiling”[mh] OR “gene expression”[mh]) AND 1990: 2007[dp] AND Eng[lang] NOT (animals[mh] NOT humans[mh]) OR review[pt]) | 1947