# Appendix E: Technical Experts and Peer Reviewers

## Technical Experts and Peer Reviewers

- Katrina Armstrong, M.D., M.S.C.E.^*^
  * Evaluation of Genomic Applications in Practice and Prevention (EGAPP) working group member.
- Director of Research
- Leonard Davis Institute of Health Economics
- University of Pennsylvania School of Medicine
- Philadelphia, PA

- Richard A. Bender, M.D., F.A.C.P.
- Medical Director-Oncology
- Quest Diagnostics Nichols Institute-SJC
- San Juan Capistrano, CA

- Lyndsay N. Harris, M.D.
- Assoc Prof Med
- Dir Breast Cancer Disease Unit and Int Med
- Medical Oncology
- 333 Cedar St
- New Haven, CT

- Daniel F. Hayes, M.D.
- University of Michigan
- Comprehensive Cancer Center
- Ann Arbor, MI

- Charles Perou, Ph.D.
- University of North Carolina, Chapel Hill
- Department of Genetics
- Chapel Hill, NC

- Kathryn Phillips, Ph.D.^*^
- Prof. of Health Economics and Health Services Research
- School of Pharmacy, Institute for Health Policy Studies, and UCSF Comprehensive Cancer Center
- University of California, San Francisco
- San Francisco, CA

- Margaret Piper, M.P.H., Ph.D.^*^
- Associate Director
- Blue Cross/Blue Shield Association
- Technology Evaluation Center

- Steve Teutsch, M.D., M.P.H.^*^
- Executive Director of Outcomes Research
- Merck & Co., Inc.
- West Point, PA

- Steven Shak, M.D.
- Chief Medical Officer
- Genomic Health
- Redwood City, CA

- Richard Simon, D.Sc.
- NCI
- Chief, Biometric Research Branch
- Rockville, MD

- Laura van't Veer, Ph.D.
- Netherlands Cancer Institute
- Amsterdam
- The Netherlands

## Internal Technical Experts

- Giovanni Parmigianni, M.S., Ph.D.
- Johns Hopkins University
- School of Medicine, Oncology Bioinformatics
- 550 Building, 11-03
- Baltimore, MD

- Antonio C. Wolf, M.D.
- Johns Hopkins University
- School of Medicine, Oncology Center
- CRB 189
- 1650 Orleans Street
- Baltimore, MD