# Appendix D: Technologies

## Reverse Transcription-Polymerase Chain Reaction (RT-PCR) and Real-Time RT-PCR

Reverse transcription polymerase chain reaction (RT-PCR) is a molecular biology technique for amplifying a specific piece of a ribonucleic acid (RNA) molecule. The RNA molecule is first reverse transcribed into complementary DNA (cDNA), followed by amplification of the resulting DNA by polymerase chain reaction (PCR), which is the common method used to amplify specific parts of a DNA molecule, via the temperature-mediated enzyme DNA polymerase. PCR uses specific short oligonucleotides, defined as primers, complementary to the target sequence to be amplified that serve to prime the polymerase reaction. The sequence of such oligonucleotides is responsible for the specificity of the reaction for the target nucleic acid fragment under analysis. PCR proceeds through subsequent amplification cycles determined by controlled temperature shifts of the reaction mixture. Real-time polymerase chain reaction is a laboratory technique that allows amplifying and quantifying simultaneously the specific part of the nucleic acid sequence under analysis. In this technique, the DNA quantity produced after each round of amplification is obtained by alternative methods. The most common quantification protocols are based on the use of fluorescent dyes that intercalate with double-strand DNA, or on modified DNA oligonucleotide probes that fluoresce when hybridized with the complementary DNA.

Real-time RT-PCR is the combination of the described techniques and enables gene expression evaluation at a particular time, or in a particular cell or tissue type. This technique is extremely sensitive and has been used to measure RNA from a single cell. The development of novel chemistries and instrumentation platforms has led to widespread use of this approach to measure gene expression changes. Moreover, this technique has become the preferred way to validate results obtained from microarray analyses and other techniques that evaluate gene expression changes on a global scale.

### RT-PCR procedures

During PCR amplification, template, product and reagent relative ratios vary. At the beginning of the reaction, reagents are in excess, template and products are at low concentrations. In this phase they do not compete for primer binding, so that the amplification proceeds at an exponential rate. Following this initial phase the reaction enters a linear phase of amplification, in which annealing of the PCR products competes with primers for binding. Following this phase, in late reaction cycles, the amplification reaches a plateau and no more PCR products accumulate. Accurate and precise quantitative data are collected during the exponential phase of the amplification, in which amplification is extremely reproducible. In real-time PCR this process is automated and measurements are made at each cycle.

Several options are currently available to perform RT-PCR and real time RT-PCR: TaqMan^®^ (Applied Biosystems, Foster City, CA, USA), Molecular Beacons, Scorpions^®^ and the use of SYBR^®^ Green (Molecular Probes). In all of these technologies PCR products are detected by generation of a fluorescent signal. TaqMan^®^ probes, Molecular Beacons and Scorpions^®^ rely on Förster Resonance Energy Transfer (FRET): a dye molecule and a quencher moiety are bound to the same or different oligonucleotide substrates and fluorescence is emitted when they are separated. SYBR Green is a fluorogenic dye that emits a strong fluorescent signal upon binding to double-stranded DNA.

### TaqMan probes

TaqMan technology depends on the 5′- nuclease activity of the DNA polymerase used for PCR. This activity is used to separate the quencher and the dye, releasing FRET and thus producing fluorescence. During the reaction, this enzyme hydrolyzes the oligonucleotide probes that are hybridized to the target sequence, decoupling occurs, and fluorescence arises, increasing at each cycle, proportional to the amount of probe cleavage.

### Molecular beacons

Molecular Beacons also is based on FRET, although the design of the probes is different. In this chemistry, a dye is attached to the 5′ end and a quencher is bound to the 3′ end of an oligonucleotide substrate. The 5′- nuclease activity of the DNA polymerase is not required since Molecular Beacons probes in solution form a loop structure that prevents fluorescing, while after hybridization to the target sequence, the dye and quencher are separated, FRET is release, and light is emitted upon irradiation.

### Scorpions

Scorpion technology assembles the amplification primer and the reporter sequence into the same oligonucleotide. In solution, the dye is attached to the 5′ end of the probe and is quenched by a moiety coupled to a complementary sequence, linked to the primer at the 3′ end, through a non-amplifiable monomer. During PCR, after extension of the Scorpion primer, the two specific probe sequences are able to bind each other, thus opening up the hairpin loop, releasing quenching and causing signal emission.

### SYBR Green

SYBR Green binds double-stranded DNA, and upon excitation fluoresces. The more PCR products accumulate, the more light emission increases. SYBR® Green is sensitive, inexpensive, and easy to use. However it binds to any double-stranded DNA molecule in the reaction, including primer-dimers and other non-specific reaction products, and this may result in an overestimation of the target molecule concentration. Since this dye binds to double-stranded DNA, there is no need to design specific probes for any particular target under analysis.

### Real-time reporters for Multiplex PCR

Several implementations of this technique (TaqMan, Molecular Beacons and Scorpions) allow multiple DNA species to be measured in the same sample (multiplex PCR). Fluorescent dyes with different emission spectra, indeed, may be coupled to the different probes assaying different targets. This approach allows the use of internal controls, which can be co-amplified along with the target sequence under analysis in the same reaction tube. Multiplex is not possible with SYBR Green.

### Quantitation of results

Two methods are commonly used to quantify the results obtained by real-time RT-PCR:

1 The standard curve method;
2 Comparative threshold method;

### The standard curve method

In this method, a standard curve is obtained from a nucleic acid template of known concentration, serially diluted. This curve is subsequently used as a reference to extrapolate quantitative information about mRNA targets of unknown concentrations. Such standards can be RNA molecules transcribed in vitro from cDNA plasmids, or other nucleic acid templates prepared at the purpose. cDNA plasmids are the preferred standards used to obtain the standard curve, however, their use will not allow inferences about the efficiency of the reverse transcription reaction, or about possible differences in the RNA template inputs. For this reason normalization to one or more housekeeping genes is often used.

### Comparative threshold method

This approach involves the comparison of the cycle threshold (CT) values of the samples of interest to the CT values of a control RNA sample, after internal normalization of each CT to an appropriate endogenous housekeeping gene. For this method to be valid, the amplification efficiencies of the target and the endogenous reference must be similar. If a housekeeping gene cannot be found, whose amplification efficiency is similar to the target, then the standard curve method is better.

### Instrumentation for Real-time RT-PCR

Real-time RT-PCR requires platforms consistency of a thermal cycler, a computer, optics for fluorescence excitation and emission collection, and data acquisition and analysis software. Such instrumentation, available from several manufacturers, varies in term of sample capacity (single tubes, 96-well, 384-well formats), excitation method, and overall sensitivity.

## DNA Microarrays

The introduction of automated large scale sequencing, supported by adequate computational tools and bioinformatics development, has greatly increased our general knowledge on genomic sequences organization and function. This knowledge is the basis for gene expression investigation on a global scale by parallel analysis of thousands of genes in a single assay. In microarray analysis, the Northern blotting scheme is reversed: the labeled moiety is obtained from the RNA sample and a certain number of immobilized known sequences are used as probes (Baldwin, Crane et al. 1999). The advances made in attaching nucleic acid sequences to glass supports and robotics allowed investigators to miniaturize the scale of the reactions. Modified microscope slides could be used to deposit thousands of nucleic acid sequences. The same result was also obtained by borrowing photolithography techniques from semiconductor manufacturing to synthesize oligonucleotides directly onto a solid support (Watson, Mazumder et al. 1998). Altogether, these advances led to in 1995, to the first papers in which the term “microarray” was used in its current meaning (Schena, Heller et al. 1998).

### Principles of microarray analysis

All the different technical solutions that have been so far developed to perform microarray analysis are miniaturized hybridization assays that allow investigators to simultaneously query thousands of nucleic acid fragments. All microarray systems share the following key components:

- The array, which contains the immobilized nucleic acid sequences, known as “probes”;
- One or more labeled samples or “targets”, that are hybridized against the microarray;
- A detection system that quantify the hybridization signals

### Microarrays and DNA-chips

Spotted microarrays consist of a collection of preformed nucleic acid sequences immobilized onto the solid support so that each unique sequence forms a tiny feature called “spot” or feature. These nucleic acids are obtained in numerous ways, and there are different methods for depositing them onto microarray slides (by simple contact, by ink-jet technology, or by micro-syringe pumping for instance). In general, nucleic acid prepared for deposition on microarrays consist of cDNA clones amplified by polymerase chain reaction (cDNA microarrays), or of synthesized oligonucleotides of various length (oligonucleotide microarrays, i.e., microarrays from Agilent Technologies). The size of the spots differs from one system to another, but it is usually less than two hundred micrometers in diameter. A modified glass slide or glass wafer acts as the solid support onto which up to tens of thousands of spots can be arrayed in a total area of a few square centimetres. On the contrary, DNA-chips are produced by a proprietary technology (GeneChip®, Affymetrix) quite different from the spotted one, as it is based on direct photolithography synthesis of short oligonucleotides (20–25 base pairs) on the solid support.

### Target labeling

Whatever the kind of microarray used, DNA probes present on the arrays are interrogated by nucleic acid hybridization with a labeled target. The sample may be mRNA for a gene expression study or genomic DNA for other purposes (promoter usage analysis: CHIP-on-Chip, genomic rearrangements: FISH-on Chip). The sample is converted to a labeled population of nucleic acids, known as the target. These moieties consist of several thousands of different labeled nucleic acid fragments and the final complexity is much greater than the one usually encountered in other routine molecular biology experiments. Therefore, these hybridizations should be carried out under conditions that do not promote annealing of non-complementary fragments. Fluorescent dyes, and especially the cyanine dyes Cy3 and Cy5, have been widely adopted as the predominant labels in microarray analysis. Fluorescence has the advantage of permitting the detection of two or more different signals in one experiment. This has thus allowed investigators to perform comparative analysis of two or more samples on one microarray. The described scheme is usually adopted for cDNA microarray analysis, while single channel experiments are the best-suited choice for GeneChip® technology, thanks to the high manufacturing reproducibility of the chips. The use of fluorescence has also increased the accuracy and throughput of microarray analysis over filter-based macroarrays, in which only one radioactively labeled sample can be conveniently analyzed at a time.

### Microarray hybridization

In a microarray hybridization, the labeled fragments in the target are expected to form duplexes with their immobilized complementary probes. This requires that the nucleic acids are single-stranded and accessible to each other. The number of duplexes formed reflects the relative number of each specific fragment in the target, as long as the amount of immobilized nucleic acid probe is in excess and not restraining the kinetics of hybridization. Two or more samples labeled with different fluorescent dyes can be hybridized simultaneously, resulting in simultaneous hybridization taking place at each spot. By measuring the different fluorescent signals associated with each feature, the relative abundance of specific sequences in each of the samples can be determined.

### Scanning and data analysis

Microarray scanners typically contain two different lasers that emit light at wavelengths that are suitable for exciting the fluorescent dyes used as labels. A detector system attached to a confocal microscope records the emitted light from each feature of the array, permitting high-resolution detection of the hybridization signals. Alternative solutions use CCD-camera devices to detect the fluorescence. Despite their small size, microarrays allow the generation of a large amount of data even from a single hybridization. For these reasons the use of computerized data processing is necessary in order to handle the amount of generated data and to gain maximum information from the experiment. This is usually achieved by specialized software that extracts primary data from scanned microarray slide images, normalizes this data to remove the influence of experimental variation, and finally manipulates the data so that biologically meaningful conclusions can be made.

### Applications of microarray analysis

The versatility of microarray analysis is confirmed by its rapid emergence as a general molecular biology analytical technique. An increasing number of researchers are now exploiting this technology in diverse biomedical disciplines. In fact, microarrays have not replaced established techniques, but rather represent a high-power approach to perform analyzes that were previously time consuming. By using information derived from the several complete or near complete genome sequences, including the human genome, it is now possible to perform genome-wide experiments using microarray technology. This has already been demonstrated for Saccaromyces Cerevisiae where all the expressed genes are known (Chu, DeRisi et al. 1998; Spellman, Sherlock et al. 1998). Due to the availability of millions of data points at once, microarrays enabled global analysis of fundamental biological processes: gene expression analysis, genome analysis, and drug discovery have been three of the main areas in which microarray analysis has been applied so far.

### Gene expression analysis

Gene expression analysis examines the composition of cellular messenger RNA populations. The identity of transcripts that make up these populations and their expression levels are informative of the cell state and of the activity of the genes and, as the precursors of translated proteins, changes in mRNA levels are related to changes in the proteome. In the simplest scheme a typical microarray gene expression experiment compares the relative expression levels of specific transcripts in two samples. Usually one of the samples is a control while the other is obtained from cells whose response or status is being explored. Each one of the two samples is labeled with a different fluorescent dye, and equal amounts of the labeled samples are combined and hybridized with the microarray. After hybridization, two grey scale images (usually in a 16-bit TIFF format) corresponding to the fluorescent signals of the two dyes are independently obtained by scanning the microarray and fluorescence intensity from each feature is subsequently quantified by a specific software. After normalization, the intensity of the two hybridization signals can be compared: equal signal from both samples suggests equal expression of the considered genes in both samples, while signals' disparity is suggestive of differential expression.

One of the most important remarks that has to be taken into account is that microarray analysis does not give any information about absolute gene expression levels in the samples. This is because the intensity of the fluorescent signals is not only proportional to the number of hybridized fragments, but also to the length of these fragments and the number of fluorescent labels each fragment carries (specific activity of the target or labeling density). These parameters are determined by the unique nucleotide sequence of each transcript, so that they will vary from gene to gene. If the two samples have been labeled under similar conditions, the length and labeling density of specific transcripts will be similar, allowing the comparison of the relative abundance of the transcripts in the analyzed targets. For these reasons a strong hybridization signal from microarray analysis does not necessarily correspond to a highly expressed gene, as it could be derived, for instance, from a gene that is expressed at a relatively low level but yields highly labeled target fragments.

Gene expression analysis with microarrays has been applied to numerous mammalian tissues, plants, yeast, and bacteria (Braxton and Bedilion 1998; Mirnics 2001; Mirnics, Middleton et al. 2001; Schulze and Downward 2001; van Berkum and Holstege 2001). These studies have examined the effects of treating cells with chemicals, the consequences of over-expression of regulatory factors in transfected cells, and compared mutant strains with parental strains to delineate functional pathways. In cancer research, microarrays have been used to find gene expression changes in transformed cells and metastases, to identify diagnostic markers, and to classify tumors based on their gene expression profiles (DeRisi, Penland et al. 1996; Alizadeh, Eisen et al. 1999; Alizadeh, Ross et al. 2001; Rew 2001, van't Veer et al. 2002).

### Genomic analysis

In addition to gene expression analysis, microarrays are now also established tools for genomic analysis (Shoemaker, Schadt et al. 2001). Microarrays, in fact, can be used to reveal transcription factor interactions with specific sequences and motifs regulating gene expression. For example, by combining immunoprecipitation of transcription factor-DNA complexes to microarray identification of DNA fragments on a genomic microarray, it was possible to identify functional regulatory elements in the yeast genome (Lieb, Liu et al. 2001). Furthermore, microarrays were used to predict splice variants of transcripts and investigate genomic fragments derived from genetic analysis methods, such as genomic mismatch scanning and representational difference analysis (Hu, Madore et al. 2001; Meltzer 2001) and specific oligonucleotide microarrays have been applied to the analysis of known single nucleotide polymorphisms (SNPs) and mutations (Sapolsky, Hsie et al. 1999; Larsen, Christiansen et al. 2001). Moreover, microarray hybridization can also be used to sequence DNA samples, thus providing a suitable mean for identifying new genetic variants (Drobyshev, Mologina et al. 1997).

### Drug discovery

A typical drug discovery process needs several years of research and only a few candidate compounds result at the end in approved drugs. For these reasons methods that increase the efficiency of the process and improve the probability of developing effective drugs are needed. In this perspective microarray analysis proved useful in different stages of drug discovery (Lockhart and Winzeler 2000; Meltzer 2001; van Berkum and Holstege 2001). For instance, the identification of potential therapeutic compounds can be achieved by elucidating metabolic pathways by looking for co-expressed. Once the drug candidates have been selected, microarrays can be subsequently used to define their toxic properties by examining expression profiles induced by drug treatments (Jain 2000). Moreover, the gene expression changes elicited by different drug treatments were also recently used to recognize their mechanisms of action (Jain 2000).

## Specific Gene Expression Based Assays

### Oncotype DX™ process

Oncotype DX is a multi-gene assay, designed to provide a quantitative assessment of the likelihood of breast cancer distant recurrence. Oncotype DX is offered by Genomic Health, where the assay was developed. The assay accounts for the following procedures: RNA is extracted and purified from the tumor specimen, then the level of expression of 21 genes (16 cancer related and 5 control genes) is obtained by RT-PCR, finally the Recurrence Score™ is calculated from the gene expression results.

In the current implementation of the assay, a pathologist at Genomic Health reviews the tumor content of the specimens to be processed, then RNA is extracted from formalin-fixed, paraffin-embedded (FFPE) specimens and contaminant DNA is removed by DNase I treatment. Total RNA yield is measured and the absence of DNA contamination is verified. Real time RT-PCR is the performed by TaqMan® technology in 384-well plates. The expression of the 16 cancer genes is measured in triplicate then normalized to the expression levels of the 5 reference genes. Finally, normalized gene expression levels of the 16 cancer related genes are used to compute the Recurrence Score (RS), on a scale form 1 to 100. Clinical studies showed the correlation of the RS with the likelihood of distant recurrence at 10 years, which increases continuously with increase of the RS, however three distinct group of risk were defined: low-risk (RS < 18), intermediate-risk (RS 18–30), and high-risk (RS ≥ 31) (Paik, Shak et al. 2004). The Oncotype DX test is offered to patients who meet the following criteria:

- Newly diagnosed
- Will be treated with tamoxifen;
- Stage I invasive breast cancer with ER positive;
- Stage II invasive breast cancer with ER positive and lymph node negative.

### MammaPrint®

MammaPrint is a multi-gene microarray-based, diagnostic assay, designed to provide a quantitative prediction of risk of metastasis in breast cancer patients. The assay measures in triplicate the expression levels of 70 distinct genes, which were originally identified in a research performed at the Netherlands Cancer Institute (Amsterdam, The Netherlands) (van 't Veer, Dai et al. 2002; van de Vijver, He et al. 2002). According to this test, patients are divided into two risk groups, with different prognosis, by measuring the cosine correlation between the 70-gene expression profile of each individual patient to the original signature developed, according to a pre-specified threshold.

The CE-marked, FDA cleared assay is offered by the certified (QSR/GMP, ISO 17025, CLIA (#99D1030869) and CAP) Agendia laboratory (Amsterdam, The Netherlands), with the following features:

- The assay is performed from fresh (non-FFPE) specimens;
- A validated sampling and transportation method of fresh tissue on ambient temperature;
- A histologic review of the shipped specimens;
- RNA extraction and quality evaluation prior to microarray analysis;
- Triplicate gene expression measurements and duplicate sample measurements, in a dye-swap design;
- Use of a constant, standardized reference RNA in each hybridization;

The MammaPrint test is offered to patients who meet the following criteria:

- Below age 61;
- Stage I invasive breast cancer with ER positive or ER negative;
- Stage II invasive breast cancer with ER positive or ER negative and lymph node negative;
- Tumor size less than 5 cm.

### Breast Cancer Profiling (BCP or H/I ratio)

The Breast Cancer Profiling (BCP) assay is based on the two-gene expression index (HOXB13/IL17BR) developed by Ma and colleagues (Ma, Wang et al. 2004; Ma, Hilsenbeck et al. 2006). Gene expression levels for the two genes are measured by real time RT-PCR, normalized to a specific set of reference genes, prior the index computation. The two-gene index is a continuous marker of recurrence risk in untreated ER-positive, node negative patients. This assay is licensed by AviaraDX to Quest Diagnostic, and it is offered as a laboratory service, with the following features:

- The assay is performed from FFPE specimens;
- Laser capture microdissection is performed if the specimen content is <30% cancer cells;
- RNA preparation and quality evaluation;
- Real-time PCR analysis of HOXB13 and IL-17BR gene expression;
- Formulation of the normalized two-gene expression index;
- Result formulation with 5-year recurrence risk;

The BCP assay is offered to patients who meet the following criteria:

- Treatment-naïve individuals with ER-positive/lymph node-negative breast cancer

#### Bibliography

Alizadeh A, Eisen M, et al. ((1999)). The lymphochip: a specialized cDNA microarray for the genomic-scale analysis of gene expression in normal and malignant lymphocytes. Cold Spring Harb Symp Quant Biol.
Alizadeh AA, Ross DT, et al. ((2001)). Towards a novel classification of human malignancies based on gene expression patterns. J Pathol.
Baldwin D, Crane V, et al. ((1999)). A comparison of gel-based, nylon filter and microarray techniques to detect differential RNA expression in plants. Curr Opin Plant Biol.
Braxton S, Bedilion T. ((1998)). The integration of microarray information in the drug development process. Curr Opin Biotechnol.
Chu S, DeRisi J, et al. ((1998)). The transcriptional program of sporulation in budding yeast. Science.
DeRisi J, Penland L, et al. ((1996)). Use of a cDNA microarray to analyse gene expression patterns in human cancer. Nat Genet.
Drobyshev A, Mologina N, et al. ((1997)). Sequence analysis by hybridization with oligonucleotide microchip: identification of beta-thalassemia mutations. Gene.
Hu GK, Madore SJ, et al. ((2001)). Predicting splice variant from DNA chip expression data. Genome Res.
Jain KK. ((2000)). Applications of biochip and microarray systems in pharmacogenomics. Pharmacogenomics.
Larsen LA, Christiansen M, et al. ((2001)). Recent developments in high-throughput mutation screening. Pharmacogenomics.
Lieb JD, Liu X, et al. ((2001)). Promoter-specific binding of Rap1 revealed by genome-wide maps of protein-DNA association. Nat Genet.
Lockhart DJ, Winzeler EA. ((2000)). Genomics, gene expression and DNA arrays. Nature.
Ma XJ, Hilsenbeck SG, et al. ((2006)). The HOXB13:IL17BR expression index is a prognostic factor in early-stage breast cancer. J Clin Oncol.
Ma XJ, Wang Z, et al. ((2004)). A two-gene expression ratio predicts clinical outcome in breast cancer patients treated with tamoxifen. Cancer Cell.
Meltzer PS. ((2001)). Spotting the target: microarrays for disease gene discovery. Curr Opin Genet Dev.
Mirnics K. ((2001)). Microarrays in brain research: the good, the bad and the ugly. Nat Rev Neurosci.
Mirnics K, Middleton FA, et al. ((2001)). Analysis of complex brain disorders with gene expression microarrays: schizophrenia as a disease of the synapse. Trends Neurosci.
Paik S, Shak S, et al. ((2004)). A multigene assay to predict recurrence of tamoxifen-treated, node-negative breast cancer. N Engl J Med.
Rew DA. ((2001)). DNA microarray technology in cancer research. Eur J Surg Oncol.
Sapolsky RJ, Hsie L, et al. ((1999)). High-throughput polymorphism screening and genotyping with high-density oligonucleotide arrays. Genet Anal.
Schena M, Heller RA, et al. ((1998)). Microarrays: biotechnology's discovery platform for functional genomics. Trends Biotechnol.
Schulze A, Downward J. ((2001)). Navigating gene expression using microarrays—a technology review. Nat Cell Biol.
Shoemaker DD, Schadt EE, et al. ((2001)). Experimental annotation of the human genome using microarray technology. Nature.
Spellman PT, Sherlock G, et al. ((1998)). Comprehensive identification of cell cycle-regulated genes of the yeast Saccharomyces cerevisiae by microarray hybridization. Mol Biol Cell.
van 't Veer LJ, Dai H, et al. ((2002)). Gene expression profiling predicts clinical outcome of breast cancer. Nature.
van Berkum NL, Holstege FC. ((2001)). DNA microarrays: raising the profile. Curr Opin Biotechnol.
van de Vijver MJ, He YD, et al. ((2002)). A gene-expression signature as a predictor of survival in breast cancer. N Engl J Med.
Watson A, Mazumder A, et al. ((1998)). Technology for microarray analysis of gene expression. Curr Opin Biotechnol.