# Appendix C: Description of Genes

ONCOTYPE™: the 21-gene signature

Acc | UGCluster | Name | Symbol | EGID | UGRepAcc | LLRepProtAcc | Chromosome | Cytoband
NM_001101 | Hs.520640 | Actin, beta | ACTB | 60 | AK125561 | NP_001092 | 7 | 7p15-p12
NM_002046 | Hs.544577 | Glyceraldehyde-3-phosphate dehydrogenase | GAPDH | 2597 | BF983396 | NP_002037 | 12 | 12p13
NM_001002 | Hs.546285 | Ribosomal protein, large, P0 | RPLP0 | 6175 | BQ051850 | NP_444505 | 12 | 12q24.2
NM_000181 | Hs.255230 | Glucuronidase, beta | GUSB | 2990 | AK096764 | NP_000172 | 7 | 7q21.11
NM_003234 | Hs.529618 | Transferrin receptor (p90, CD71) | TFRC | 7037 | BC001188 | NP_003225 | 3 | 3q29
NM_002417 | Hs.80976 | Antigen identified by monoclonal antibody Ki-67 | MKI67 | 4288 | NM_002417 | NP_002408 | 10 | 10q25-qter
NM_003600 | Hs.250822 | Aurora kinase A | AURKA | 6790 | NM_198433 | NP_940839 | 20 | 20q13.2–q13.3
NM_001168 | Hs.514527 | Effector cell peptidase receptor 1 | EPR1 | 8475 | NM_001012271 | | 17 | 17q25
NM_031966 | Hs.23960 | Cyclin B1 | CCNB1 | 891 | NM_031966 | NP_114172 | 5 | 5q12
NM_002466 | Hs.179718 | V-myb myeloblastosis viral oncogene homolog (avian)-like 2 | MYBL2 | 4605 | BX647151 | NP_002457 | 20 | 20q13.1
NM_004448 | Hs.446352 | V-erb-b2 erythroblastic leukemia viral oncogene homolog 2, neuro/glioblastoma derived oncogene homolog (avian) | ERBB2 | 2064 | NM_001005862 | NP_004439 | 17 | 17q11.2–q12\|17q21.1
NM_005310 | Hs.86859 | Growth factor receptor-bound protein 7 | GRB7 | 2886 | NM_005310 | NP_005301 | 17 | 17q12
NM_000043 | Hs.244139 | Fas (TNF receptor superfamily, member 6) | FAS | 355 | AB209361 | NP_690616 | 10 | 10q24.1
NM_000926 | Hs.368072 | Progesterone receptor | PGR | 5241 | X51730 | NP_000917 | 11 | 11q22–q23
NM_000633 | Hs.150749 | B-cell CLL/lymphoma 2 | BCL2 | 596 | NM_000633 | NP_000648 | 18 | 18q21.33\|18q21.3
NM_020974 | Hs.523468 | Signal peptide, CUB domain, EGF-like 2 | SCUBE2 | 57758 | NM_020974 | NP_066025 | 11 | 11p15.3
NM_005940 | Hs.143751 | Matrix metallopeptidase 11 (stromelysin 3) | MMP11 | 4320 | NM_005940 | NP_005931 | 22 | 22q11.2\|22q11.23
NM_001333 | Hs.660866 | Cathepsin L2 | CTSL2 | 1515 | BC067289 | NP_001324 | 9 | 9q22.2
NM_000561 | Hs.301961 | Glutathione S-transferase M1 | GSTM1 | 2944 | BQ880398 | NP_666533 | 1 | 1p13.3
NM_001251 | Hs.647419 | CD68 molecule | CD68 | 968 | NM_001251 | NP_001242 | 17 | 17p13
NM_004323 | Hs.377484 | BCL2-associated athanogene | BAG1 | 573 | NM_004323 | NP_004314 | 9 | 9p12

MAMMAPRINT®: the 70-gene signature

ORIGINALID | Acc | UGCluster | Name | Symbol | LLID | UGRepAcc | LLRepProtAcc | Chromosome | Cytoband
AA555029_RC | AA555029 | Hs.100691 | Hypothetical protein LOC286052 | LOC286052 | 286052 | AK095104 | | 8 | 8q24.13
AF052162 | AF052162 | Hs.368853 | Acyltransferase like 2 | AYTL2 | 79888 | AK090444 | NP_079106 | 5 | 5p15.33
NM_007203 | NM_007203 | Hs.591908 | PALM2-AKAP2 protein | PALM2-AKAP2 | 445815 | NM_053016 | NP_671492 | 9 | 9q31–q33
AL080059 | AL080059 | Hs.173094 | TSPY-like 5 | TSPYL5 | 85453 | NM_033512 | NP_277047 | 8 | 8q22.1
AL137718 | AL137718 | Hs.283127 | Diaphanous homolog 3 (Drosophila) | DIAPH3 | 81624 | NM_001042517 | NP_112194 | 13 | 13q21.2
NM_003748 | NM_003748 | Hs.77448 | Aldehyde dehydrogenase 4 family, member A1 | ALDH4A1 | 8659 | NM_003748 | NP_733844 | 1 | 1p36
NM_001282 | NM_001282 | Hs.514819 | Adaptor-related protein complex 2, beta 1 subunit | AP2B1 | 163 | NM_001030006 | NP_001273 | 17 | 17q11.2–q12
U82987 | U82987 | Hs.467020 | BCL2 binding component 3 | BBC3 | 27113 | AF332558 | NP_055232 | 19 | 19q13.3–q13.4
NM_004702 | NM_004702 | Hs.567387 | Cyclin E2 | CCNE2 | 9134 | NM_057735 | NP_477097 | 8 | 8q22.1
NM_020974 | NM_020974 | Hs.523468 | Signal peptide, CUB domain, EGF-like 2 | SCUBE2 | 57758 | NM_020974 | NP_066025 | 11 | 11p15.3
NM_001809 | NM_001809 | Hs.1594 | Centromere protein A | CENPA | 1058 | BM911202 | NP_001800 | 2 | 2p24-p21
AF201951 | AF201951 | Hs.530735 | Membrane-spanning 4-domains, subfamily A, member 7 | MS4A7 | 58475 | NM_032597 | NP_996823 | 11 | 11q12
X05610 | X05610 | Hs.508716 | Collagen, type IV, alpha 2 | COL4A2 | 1284 | NM_001846 | NP_001837 | 13 | 13q34
Contig20217_RC | AA834945 | Hs.604604 | Transcribed locus, moderately similar to XP_001091104.1 similar to lin-9 homolog [Macaca mulatta] | AA834945 | | AA834945 | | 1
Contig24252_RC | AW024884 | Hs.528605 | PP12104 | LOC643008 | 643008 | XM_928053 | | 17 | 17q25.1
Contig28552_RC | AA992378 | Hs.283127 | Diaphanous homolog 3 (Drosophila) | DIAPH3 | 81624 | NM_001042517 | NP_112194 | 13 | 13q21.2
Contig32125_RC | AA404325 | Hs.523036 | CDNA FLJ38245 fis, clone FCBBF2007186 | AA404325 | | AK095564 | | 1
Contig32185_RC | AI377418 | Hs.657472 | G protein-coupled receptor 180 | GPR180 | 160897 | NM_180989 | NP_851320 | 13 | 13q32.1
Contig35251_RC | AI283268 | Hs.634333 | CDNA: FLJ22719 fis, clone HSI14307 | AI283268 | | AK026372 | | 7
Contig38288_RC | AI554061 | Hs.657864 | Quiescin Q6 sulfhydryl oxidase 2 | QSOX2 | 169714 | AJ318051 | NP_859052 | 9 | 9q34.3
Contig40831_RC | AI224578 | Hs.595493 | Full-length cDNA clone CS0DI029YM01 of Placenta Cot 25-normalized of Homo sapiens (human) | AI224578 | | BF675485 | | 8
Contig46218_RC | AI813331 | Hs.283127 | Diaphanous homolog 3 (Drosophila) | DIAPH3 | 81624 | NM_001042517 | NP_112194 | 13 | 13q21.2
Contig46223_RC | AA528243 | Hs.22917 | Reticulon 4 receptor-like 1 | RTN4RL1 | 146760 | NM_178568 | NP_848663 | 17 | 17p13.3
Contig48328_RC | AI694320 | Hs.655005 | Zinc finger protein 533 | ZNF533 | 151126 | BC092423 | NP_689733 | 2 | 2q31.2–q31.3
Contig51464_RC | AI817737 | Hs.567582 | F-box protein 31 | FBXO31 | 79791 | AF318348 | NP_079011 | 16 | 16q24.2
Contig55377_RC | AI918032 | Hs.632255 | RUN domain containing 1 | RUNDC1 | 146923 | BC039247 | NP_775102 | 17 | 17q21.31
Contig55725_RC | AI992158 | Hs.470654 | Cell division cycle associated 7 | CDCA7 | 83879 | AL834186 | NP_665809 | 2 | 2q31
Contig56457_RC | AI741117 | Hs.530272 | Chromosome 9 open reading frame 30 | C9orf30 | 91283 | AK092292 | NP_542386 | 9 | 9q31.1
Contig63102_RC | AI583960 | Hs.55918 | Likely ortholog of mouse D11lgp2 | LGP2 | 79132 | AK021416 | NP_077024 | 17 | 17q21.2
Contig63649_RC | AW014921 | Hs.446388 | CDNA FLJ41489 fis, clone BRTHA2004582 | AW014921 | | AK123483 | | 11
NM_020188 | NM_020188 | Hs.388255 | Chromosome 16 open reading frame 61 | C16orf61 | 56942 | BM463756 | NP_064573 | 16 | 16q23.2
NM_000788 | NM_000788 | Hs.709 | Deoxycytidine kinase | DCK | 1633 | CD014015 | NP_000779 | 4 | 4q13.3–q21.1
AL080079 | AL080079 | Hs.318894 | G protein-coupled receptor 126 | GPR126 | 57211 | NM_020455 | NP_940971 | 6 | 6q24.1
Contig25991 | AI738508 | Hs.518299 | Epithelial cell transforming sequence 2 oncogene | ECT2 | 1894 | AY376439 | NP_060568 | 3 | 3q26.1–q26.2
NM_007036 | NM_007036 | Hs.129944 | Endothelial cell-specific molecule 1 | ESM1 | 11082 | X89426 | NP_008967 | 5 | 5q11.2
NM_000127 | NM_000127 | Hs.492618 | Exostoses (multiple) 1 | EXT1 | 2131 | NM_000127 | NP_000118 | 8 | 8q24.11–q24.13
NM_003862 | NM_003862 | Hs.87191 | Fibroblast growth factor 18 | FGF18 | 8817 | AF075292 | NP_387498 | 5 | 5q34
NM_018354 | NM_018354 | Hs.516834 | Chromosome 20 open reading frame 46 | C20orf46 | 55321 | AK126837 | NP_060824 | 20 | 20p13
NM_002019 | NM_002019 | Hs.654360 | Fms-related tyrosine kinase 1 (vascular endothelial growth factor/vascular permeability factor receptor) | FLT1 | 2321 | NM_002019 | NP_002010 | 13 | 13q12
NM_003875 | NM_003875 | Hs.591314 | Guanine monphosphate synthetase | GMPS | 8833 | NM_003875 | NP_003866 | 3 | 3q24
NM_002073 | NM_002073 | Hs.584760 | Guanine nucleotide binding protein (G protein), alpha z polypeptide | GNAZ | 2781 | BC037333 | NP_002064 | 22 | 22q11.22
NM_000849 | NM_000849 | Hs.2006 | Glutathione S-transferase M3 (brain) | GSTM3 | 2947 | NM_000849 | NP_000840 | 1 | 1p13.3
NM_006101 | NM_006101 | Hs.414407 | NDC80 homolog, kinetochore complex component (S. cerevisiae) | NDC80 | 10403 | NM_006101 | NP_006092 | 18 | 18p11.32
NM_018401 | NM_018401 | Hs.133062 | Serine/threonine kinase 32B | STK32B | 55351 | AY358353 | NP_060871 | 4 | 4p16.2-p16.1
AF055033 | AF055033 | Hs.635441 | Insulin-like growth factor binding protein 5 | IGFBP5 | 3488 | NM_000599 | NP_000590 | 2 | 2q33–q36
NM_000599 | NM_000599 | Hs.635441 | Insulin-like growth factor binding protein 5 | IGFBP5 | 3488 | NM_000599 | NP_000590 | 2 | 2q33–q36
NM_014791 | NM_014791 | Hs.184339 | Maternal embryonic leucine zipper kinase | MELK | 9833 | NM_014791 | NP_055606 | 9 | 9p13.2
AK000745 | AK000745 | Hs.377155 | Metadherin | MTDH | 92140 | BC045642 | NP_848927 | 8 | 8q22.1
AB037863 | AB037863 | Hs.471955 | Early B-cell factor 4 | EBF4 | 57593 | XM_044921 | | 20 | 20p13
NM_016448 | NM_016448 | Hs.656473 | Denticleless homolog (Drosophila) | DTL | 51514 | NM_016448 | NP_057532 | 1 | 1q32.1–q32.2
NM_016359 | NM_016359 | Hs.615092 | Nucleolar and spindle associated protein 1 | NUSAP1 | 51203 | AK222819 | NP_060924 | 15 | 15q15.1
NM_020386 | NM_020386 | Hs.36761 | HRAS-like suppressor | HRASLS | 57110 | BC048095 | NP_065119 | 3 | 3q29
NM_005915 | NM_005915 | Hs.444118 | Minichromosome maintenance complex component 6 | MCM6 | 4175 | NM_005915 | NP_005906 | 2 | 2q21
NM_004994 | NM_004994 | Hs.297413 | Matrix metallopeptidase 9 (gelatinase B, 92kDa gelatinase, 92kDa type IV collagenase) | MMP9 | 4318 | NM_004994 | NP_004985 | 20 | 20q11.2–q13.1
NM_014889 | NM_014889 | Hs.528300 | Pitrilysin metallopeptidase 1 | PITRM1 | 10531 | CR749279 | NP_055704 | 10 | 10p15.2
NM_006681 | NM_006681 | Hs.418367 | Neuromedin U | NMU | 10874 | BF034907 | NP_006672 | 4 | 4q12
NM_014321 | NM_014321 | Hs.49760 | Origin recognition complex, subunit 6 like (yeast) | ORC6L | 23594 | NM_014321 | NP_055136 | 16 | 16q12
NM_000436 | NM_000436 | Hs.278277 | 3-oxoacid CoA transferase 1 | OXCT1 | 5019 | NM_000436 | NP_000427 | 5 | 5p13.1
NM_006117 | NM_006117 | Hs.15250 | Peroxisomal D3, D2-enoyl-CoA isomerase | PECI | 10455 | AB209917 | NP_996667 | 6 | 6p24.3
AF257175 | AF257175 | Hs.15250 | Peroxisomal D3, D2-enoyl-CoA isomerase | PECI | 10455 | AB209917 | NP_996667 | 6 | 6p24.3
NM_003607 | NM_003607 | Hs.35433 | CDC42 binding protein kinase alpha (DMPK-like) | CDC42BPA | 8476 | NM_003607 | NP_055641 | 1 | 1q42.11
NM_003981 | NM_003981 | Hs.567385 | Protein regulator of cytokinesis 1 | PRC1 | 9055 | NM_003981 | NP_955446 | 15 | 15q26.1
NM_016577 | NM_016577 | Hs.12152 | RAB6A, member RAS oncogene family | RAB6A | 5870 | NM_016577 | NP_942599 | 3 | 11q13.3
NM_002916 | NM_002916 | Hs.518475 | Replication factor C (activator 1) 4, 37kDa | RFC4 | 5984 | NM_002916 | NP_853551 | 3 | 3q27
AF073519 | AF073519 | Hs.658079 | Small EDRK-rich factor 1A (telomeric) | SERF1A | 8293 | AF073519 | NP_068802 | 5 | 5q12.2–q13.3
NM_006931 | NM_006931 | Hs.419240 | Solute carrier family 2 (facilitated glucose transporter), member 3 | SLC2A3 | 6515 | AB209607 | NP_008862 | 12 | 12p13.3
Contig2399_RC | W90004 | Hs.444450 | Egl nine homolog 1 (C. elegans) | EGLN1 | 54583 | AF229245 | NP_071334 | 1 | 1q42.1
NM_003239 | NM_003239 | Hs.592317 | Transforming growth factor, beta 3 | TGFB3 | 7043 | AK122902 | NP_003230 | 14 | 14q24
NM_015984 | NM_015984 | Hs.591458 | Ubiquitin carboxyl-terminal hydrolase L5 | UCHL5 | 51377 | AK225794 | NP_057068 | 1 | 1q32
NM_003882 | NM_003882 | Hs.492974 | WNT1 inducible signaling pathway protein 1 | WISP1 | 8840 | AF100779 | NP_543028 | 8 | 8q24.1–q24.3

BCP - H/I assay: 2-gene signature and normalizing genes

Symbol | UGCluster | Name | EGID | UGRepAcc | LLRepProtAcc | Chromosome | Cytoband
ACTB | Hs.520640 | Actin, beta | 60 | AK125561 | NP_001092 | 7 | 7p15-p12
HMBS | Hs.82609 | Hydroxymethylbilane synthase | 3145 | BU168137 | NP_000181 | 11 | 11q23.3
SDHA | Hs.440475 | Succinate dehydrogenase complex, subunit A, flavoprotein (Fp) | 6389 | AK131478 | NP_004159 | 5 | 5p15
UBC | Hs.520348 | Ubiquitin C | 7316 | AB209436 | NP_066289 | 12 | 12q24.3
HOXB13 | Hs.66731 | Homeobox B13 | 10481 | AY937237 | NP_006352 | 17 | 17q21.2
IL17RB | Hs.654970 | Interleukin 17 receptor B | 55540 | NM_018725 | NP_758434 | 3 | 3p21.1

Symbol: official gene symbol

UGCCluster: Unigene cluster identifier

Name: gene name according to Unigene

EGID: Entrez Gene identifier

UGRepAcc: representative GeneBank accession number according to Unigene

LLRepProtAcc: representative Protein accession number according to Entrez Gene

Chromosome: chromosomal location

Cytoband: cytogenetic band