# Appendix A: List of Acronyms

Acronym | Definition
AHRQ | Agency for Healthcare Research and Quality
ANOVA | Analysis of variance
AUC | Area under the receiver-operating-characteristic curve
BCP | Breast Cancer Profiling
BCT | Breast conserving therapy
BIG | Breast International Group
BRCA | Breast cancer gene
CCD | Charge Coupled Devices
CDC | Centers for Disease Control and Prevention
cDNA | Complementary DNA
CENTRAL | The Cochrane Central Register of Controlled Trials
CI | Confidence Interval
CLIA | Clinical Laboratory Improvement Act
CMTP | Center for Medical Technology Policy
CR | Complete response
CT | Cycle threshold
CV | Coefficient of variation
DFS | Disease free survival
DNA | Deoxyribonucleic acid
DRFS | Distant recurrence-free survival
EGAPP | Evaluation of Genomic Applications in Practice and Prevention
EPC | The Evidence-based Practice Center
ER | Estrogen receptor
FDA | Food and Drug Administration
FFPE | Formalyn-fixed paraffin-embedded
FISH | Fluorescent in situ hybridization
FRET | Förster Resonance Energy Transfer
GEP | Gene expression profiling
HER2 | Human epidermal growth factor receptor 2
HR | Hormone Receptors
IHC | Immunohistochemical
INT | Italian National Cancer Institute of Milan, Italy
IVDMIAs | In Vitro Diagnostic Multivariate Index Assays
JHU | Johns Hopkins University
LCM | Laser-capture micro dissected
LMC | Laser micro-dissection
LOD | Limit of detection
LOQ | Limit of quality
MeSH | Medical subject heading
MIAME | Minimum Information About a Microarray Experiment
MINDACT | Microarray for Node-Negative Disease may Avoid Chemotherapy
mRNA | Messenger ribonucleic acid
NCCN | National Comprehensive Cancer Network
NCCTG | North Central Cancer Treatment Group
NCI | National Cancer Institute
NHG | Nottingham Histologic Grade
NIH | National Institutes of Health
NPI | Nottingham Prognostic Index
NSABP | National Surgical Adjuvant Breast and Bowel Project
OR | Odds Ratio
OS | Overall survival
OVID | Office of In Vitro Diagnostic evaluation and Safety
pCR | Complete pathological response
PCR | Polymerase chain reaction
PD | Progressive disease
PFS | Progression free survival
PMA | Pre-Market Approval
PR | Progesterone receptor
PR | Partial response
QALY | Quality-adjusted life-year
RCT | Randomized Controlled Trial
RECIST | Response Evaluation Criteria in Solid Tumors
REMARK | Reporting recommendations for tumour MARKer prognostic studies
RFS | Relapse Free Survival
RNA | Ribonucleic acid
ROC | Receiver operating characteristic
RR | Relative risk
RS | Recurrence Score
RT-PCR | reverse transcriptase polymerase chain reaction
SD | Standard deviation
SNP | Single nucleotide polymorphisms
STARD | Standards for Reporting of Diagnostic Accuracy
TAILORx | Trial Assigning Individualized Options for Treatment
TBCI | The North American Breast Cancer Intergroup
TRANSBIG | Translating molecular knowledge into early breast cancer management: building on the BIG (Breast International Group) network for improved treatment tailoring
TTM | Time to distant metastases
VEGF | Vascular epithelial growth factor