# Acknowledgments

The Evidence-based Practice Center thanks Michael Oladubu, D.D.S. and Allison Jonas, for their assistance with literature searching and database management, and project organization; Aly Shogan for her assistance in completing the sections on economics; Brenda Zacharko for her assistance with budget matters, and for her assistance with final preparations of the report. The Center also wishes to thank Gurvaneet Randhawa, M.D., M.P.H., AHRQ Task Order Officer, for his efforts in guiding this project and coordination with the CDC EGAPP group.