# Evidence Tables

Evidence Table 1. Overall summary of literature on anesthesia for cataract surgery

Author(s), year, and country of study | Study design | Exclusions | Number of surgeries | Study aims | Principal outcomes of study | Study limitations | Overall quality score (0-100%) | Bottom line
(1) Main Topic: Regional Anesthesia
Abelson, Mandel, Paradis et al., 1989 USA | RCT | None stated, consecutive. | 40 | To assess the effectiveness of hyaluronidase in a local block. | Akinesia; supplemental regional; sedation complications | Inadequate description of patient characteristics; inadequate report of duration of surgery | 46 | The addition of hyaluronidase improved akinesia in retrobulbar injections.
Agrawal and Athanikar, 1994 India | Case series | None stated. | 1,000 | To report the effectiveness of a single injection, low volume, periocular anesthesia. | Akinesia; supplemental regional; regional complications; recovery | Not randomized; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described | 43 | A single periocular injection of local anesthetic provided adequate lid and globe akinesia.
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | RCT | None stated. | 450 | To compare the effectiveness of two methods of peribulbar anesthesia with retrobulbar anesthesia. | Akinesia; supplemental regional; regional complications; patient satisfaction | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 58 | One peribulbar technique equivalent to and one less effective than retrobulbar.
Anderson, 1995 USA | Case series | None stated, consecutive. | 133 | To report the results of a subconjunctival anesthesia technique. | Akinesia; supplemental regional; regional complications; pain | Not randomized; inadequate detail of exclusion criteria; inadequate report of duration of surgery; can't tell if evaluations standardized | 37 | Subconjunctival anesthesia with supplemental sedation provided adequate and safe anaesthesia.
Anderson, Nath, and Anderson, 1999 USA | RCT | One refusal, one with severe head nodding. | 48 | To compare the effectiveness of intracameral bupivacaine versus intracameral lidocaine for topical anesthesia. | Pain | Not randomized | 66 | Intracameral lidocaine was equally effective as intracameral bupivacaine in controlling patient pain during topical clear corneal surgery.
Athanikar and Agrawal, 1991 India | RCT | None stated. | 142 | To compare the effectiveness of peribulbar anesthesia to retrobulbar anesthesia. | Akinesia; regional complications | Inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; analyses not appropriate | 30 | The retrobulbar and peribulbar techniques described yielded equivalent anesthesia and akinesia.
Bell and Butt, 1995 Great Britain | RCT | None stated. | 60 | To test whether warming lignocaine reduces the pain of anesthetic injection for a peribulbar technique. | Akinesia; pain | Inadequate detail of exclusion criteria; ancillary treatments not described; inadequate report of duration of surgery | 36 | Pain of peribulbar injection was less with warm lignocaine than cold lignocaine.
Bjornstrom, Hansen, Otland et al., 1994 Denmark | RCT | Patients with ocular comorbidity. | 54 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | Akinesia; supplemental regional; regional complications; pain | Inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery | 30 | Peribulbar block using adrenalin and hyaluronidase in addition to lidocaine and bupivacaine provided better analgesia and akinesia than lidocaine and bupivacaine alone.
Briggs, Beck, and Esakowitz, 1997 UK | NRT | None stated. | 131 | To compare the effectiveness of sub-Tenon's and peribulbar anesthesia. | Regional complications; pain | Not randomized; no masking; inadequate detail of exclusion criteria; ancillary treatments not described; inadequate report of duration of surgery | 26 | Results suggest that sub-Tenon's anesthesia may be less painful on administration than peribulbar and may provide better relief from pain/discomfort during surgery.
Buttery and Wise, 1989 Australia | RCT | None stated, consecutive. | 48 | To compare the effectiveness of retrobulbar anesthesia using transdermal and transconjunctival technique. | Regional complications | Inadequate description of patient characteristics | 42 | A transconjunctival approach with a curved needle achieved superior akinesia at 6 minutes than a standard percutaneous retrobulbar approach, but akinesia was equal by the end of surgery.
Carino, Slomovic, Chung et al., 1998 Canada | RCT | Dementia, confusion, systemic reaction, prior intraocular surgery. | 560 | To compare the effectiveness of topical tetracaine to topical tetracaine plus intracameral lidocaine. | Pain; patient satisfaction | Inadequate report of duration of surgery | 53 | Topical tetracaine with intracameral lidocaine gave better analgesia than topical tetracaine without intracameral lidocaine.
Chittenden, Meacock, and Govan, 1997 UK | RCT | None stated. | 35 | To compare the effectiveness of topical with sub-Tenon's anesthesia. | Pain | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery | 34 | Sub-Tenon's group had bridal suture; topical did not. Pain only associated with bridal suture. Topical used scleral tunnel, most pain with cautery, less pain with sub-Tenon's for scleral tunnel.
Corboy and Jiang, 1997 USA | X-SEC | None stated. | 2143 | To assess the cause of postoperative hypotropia after cataract surgery. | Regional complications | Not randomized; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized | 31 | Left-sided postoperative hypotropia may be due to problem with technique of right-handed injection given from the side rather than from in front of patient.
Crandall, Zabriskie, Patel et al., 1999 USA | RCT | Single eye, ASA >3. | 136 | To compare the effectiveness of topical anesthesia with and without intracameral lidocaine. | Regional complications; pain | Inadequate description of patient characteristics; inadequate report of duration of surgery; analyses not appropriate | 46 | Intracameral lidocaine provided better cooperation during surgery and less perception of eye manipulation than placebo, but slightly more corneal edema on postoperative day 1and slightly larger declines in endothelial cell count.
Davis and Mandel, 1986 USA | Case series | None stated. | 1,600 | To compare posterior peribulbar anesthesia to retrobulbar anesthesia. | Akinesia; regional complications; medical complications | Not randomized; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective | 13 | A two-injection peribulbar block appeared safe and effective.
Davis and O'Connor, 1989 Canada | RCT | None stated, consecutive. | 100 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | Akinesia; supplemental regional; medical complications; sedation complications | Inadequate description of patient characteristics; ancillary treatments not described | 53 | Lidocaine alone equaled lidocaine plus bupivacaine for akinesia achieved with this peribulbar technique.
Demirok, Simsek, Cinal et al., 1997 Turkey | RCT | None stated. | 120 | To compare the effectiveness of one versus two injections of peribulbar anesthesia. | Akinesia; supplemental regional; regional complications; pain | Inadequate detail of exclusion criteria; ancillary treatments not described; inadequate report of duration of surgery | 33 | A single inferior peribulbar injection yielded akinesia and anesthesia equivalent to a two-injection (inferior and superior) peribulbar technique.
Dinsmore, 1995 USA | Case series | None stated. | 136 | To report an approach to topical anesthesia. | Supplemental regional | Not randomized; no masking; inadequate report of duration of surgery; evaluations not standardized; outcome assessment not objective | 34 | The case series demonstrated that adequate anesthesia can be achieved with topical lidocaine drops in 92% of cataract surgery patients.
Dinsmore, 1996 USA | X-SEC | None stated, consecutive. | 200 | To report the use of topical anesthesia for clear corneal surgery with mild IV sedation. | Pain | Not randomized; no masking; inadequate description of patient characteristics; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective | 34 | Topical anesthesia combined with low-dose midazolam provided adequate anesthesia to 97% of patients.
Dopfmer, Maloney, Gaynor et al., 1996 Germany | RCT | None stated. | 90 | To compare akinesia achieved with prilocaine versus bupivacaine plus lignocaine. | Akinesia; supplemental regional; regional complications; pain | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 43 | Prilocaine produced better akinesia than a mixture of bupivacaine and lignocaine, but analgesia was similar.
Edge, McClarty, Krige et al., 1995 Saudi Arabia | RCT | Eye disease other than cataract. | 408 | To compare retrobulbar to peribulbar anesthesia. | Supplemental regional; regional complications; sedation complications | No masking; ancillary treatments not described; inadequate report of duration of surgery | 32 | Retrobulbar injection had faster onset and required fewer supplemental injections then peribulbar.
Ellingsson and Aasved, 1979 Norway | RCT | None stated. | 92 | To compare the effectiveness of etidocaine 1% versus lidocaine 2% using retrobulbar anesthesia. | Akinesia; pain | Inadequate detail of exclusion criteria; inadequate report of duration of surgery; can't tell if evaluations standardized; analyses not appropriate | 20 | Etidocaine caused a more prolonged analgesic effect than lidocaine in the postoperative period, but lidocaine appears superior to etidocaine in inducing intraoperative akinesia and anesthesia.
Feibel, Custer, and Gordon, 1993 USA | RCT | Ocular reasons. | 317 | To assess the rates of ptosis using retrobulbar or two-injection peribulbar anesthesia. | Regional complications | Ancillary treatments not described; inadequate report of duration of surgery | 65 | Retrobulbar and peribulbar injection yielded equivalent (approximately 6%) rate of postoperative ptosis at 90 days.
Fukasaku and Marron, 1994 Japan | RCT | None stated. | 348 | To compare a topical with two subconjunctival regional anesthetic techniques. | Pain | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective; analyses not appropriate | 11 | Topical drops combined with sub-Tenon's injection produced superior pain control to topical alone or retrobulbar, and little pain was felt during anesthetic administration.
Furuta, Toriumi, Kashiwagi et al., 1990 Japan | Case series | Posterior synechiae, mental disorders, post-vitrectomy cataracts. | 176 | To assess the effectiveness of a method of sub-Tenon's anesthesia. | Regional complications; pain | Not randomized; inadequate description of patient characteristics; can't tell if evaluations standardized; outcome assessment not objective | 59 | Subconjunctival injection of lidocaine reported as effective.
Garcia, Loureiro, Limao et al., 1998 Portugal | RCT | High preoperative IOP, complicated surgery. | 59 | To compare topical anesthesia with intracameral lidocaine to peribulbar anesthesia (re: effect on corneal endothelium). | Patient satisfaction | No masking; inadequate report of duration of surgery | 39 | Equivalent endothelial cell loss.
Gillart, Bazin, Deret et al., 1996 France | RCT | None stated. | 50 | To assess the effect of the pressure on injection of local anesthesia during peribulbar block. | Akinesia; supplemental regional; pain | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 53 | Higher pressure of injection with peribulbar technique resulted in a higher rate of akinesia. No relationship could be identified between the speed of injection and quality of akinesia.
Gillart, Bazin, Montetagaud et al., 1998 France | RCT | None stated. | 140 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | Akinesia; supplemental regional; regional complications | Inadequate report of duration of surgery | 50 | Higher volume of anesthesia injected at faster rate yielded better akinesia but no increase in pain of injection compared to lower volume slower injection.
Gills, Cherchio, and Raanan, 1997 USA | RCT | Known allergy to anesthetics. | 303 | To assess the effect of unpreserved lidocaine on pain under topical anesthesia. | Akinesia; pain; medical complications; sedation complications; recovery hemodynamics | Inadequate report of duration of surgery | 55 | Intracameral lidocaine was superior to placebo in decreasing intraoperative pain and discomfort.
Guise, 1996 New Zealand | Case series | None stated. | 300 | To assess the effectiveness of sub-Tenon's block. | Supplemental regional; regional complications; pain; patient satisfaction | Not randomized; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized | 26 | Sub-Tenon's block as performed rarely required repeat injection.
Gutman, Sinskey, and Cain, 1979 USA | NRT | History of monoamine oxidase inhibitor use. | 52 | To compare the effectiveness of lidocaine compared to etidocaine for retrobulbar anesthesia. | Pain | Not randomized; inadequate report of duration of surgery | 34 | Patients receiving lidocaine had less pain at time of block than those receiving etidocaine, but etidocaine produced a longer duration of anesthesia.
Hamilton and Claoue, 1998 UK | NRT | None reported. | 40 | To compare topical proxymetacaine to topical tetracaine for clear-cornea surgery using intracameral lidocaine. | Pain | Not randomized; no masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery | 39 | No difference between tetracaine and proparacaine in intraoperative, postoperative pain. Proparacaine had less stinging on instillation.
Hamilton, Gimbel, and Strunin, 1988 Canada | Cohort | None reported. | 12,000 | To assess the safety and effectiveness of 12,000 regional anesthetics administered by one doctor using five different techniques of injection anesthesia. | Akinesia; supplemental regional; regional complications; medical complications | Not randomized; no masking; inadequate detail of exclusion criteria; inadequate report of duration of surgery | 32 | Peribulbar with optional use of retrobulbar and lid block reported as safest and most effective.
Henderson and Franks, 1996 UK | RCT | None stated, consecutive. | 75 | To compare the effectiveness of prilocaine 2% and a combination of lignocaine 1% and bupivacaine 0.5%. | Supplemental regional; regional complications; pain; patient satisfaction | Inadequate description of patient characteristics; ancillary treatments not described; can't tell if evaluations standardized | 37 | Prilocaine had slightly more individuals reporting pain than lidocaine/bupivacaine. However, block was given on average 45 minutes before the case and pain with prilocaine was associated with time since injection.
Hendrick, Rosenberg, and Lebenbom-Mansour, 1997 USA | Case series | None stated, consecutive. | 1,074 | To report the effectiveness and safety of peribulbar block performed by anesthesiologists. | Akinesia; supplemental regional; regional complications; sedation complications | Not randomized; evaluations not standardized | 75 | Peribulbar anesthesia can be effective when administered by an anesthesiologist.
Hinshaw, Fiscella, and Sugar, 1995 USA | RCT | Diabetes, cardiac medications. | 21 | To compare pH-adjusted retrobulbar block with nonadjusted block. | Supplemental regional; pain | Inadequate description of patient characteristics; inadequate report of duration of surgery | 38 | pH-buffered anesthetic appeared to produce better analgesia with retrobulbar blockade than did nonbuffered solution, but pain scores were higher than typically reported.
Hodgkins, Teye-Botchway, Morrell et al., 1992 UK | Case series | Incomplete followup. | 1,817 | To assess the effectiveness of a combination of intravenous sedation, facial nerve block, and topical anesthesia. | Regional complications; medical complications; sedation complications; | Not randomized; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective | 50 | Intravenous sedation combined with facial nerve block appeared to be a safe method of anesthesia for cataract surgery.
Hosal, Tekeli, and Gursel, 1998 Turkey | Case series | Patients with thyroid eye disease, external eye disease, and prior lid surgery. | 124 | To estimate the rate of and risk factors for eyelid malpositions following cataract surgery. | Regional complications | Not randomized; ancillary treatments not described | 44 | 7.3% of patients had 2 millimeters or more of new ptosis 6 months following cataract surgery. Development of ptosis was more likely with longer operative time.
House, Hollands, and Schulzer, 1991 Canada | RCT | None stated, consecutive. | 117 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | Akinesia; pain | Inadequate description of patient characteristics | 51 | Combination of lidocaine 0.66% and bupivacaine 0.5% with both epinephrine and hyaluronidase produced superior akinesia.
Huha, Ala-Kokko, Salomaki et al., 1999 Finland | RCT | None stated. | 100 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | Akinesia; supplemental regional; pain | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 60 | Ropivacaine had slightly more rapid onset of action than bupivacaine. Pain control was equal.
Johansen, Kjeldgard, and Corydon, 1993 Denmark | RCT | Patients with ocular comorbidity and retrobulbar hemorrhage. | 139 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | Akinesia; supplemental regional | Inadequate description of patient characteristics; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective | 28 | Lidocaine plus marcaine plus epinephrine plus hyaluronidase yielded the most effective blocks.
John, 1998 USA | Case series | None stated consecutive. | 102 | To describe a technique combining topical and intracameral anesthesia. | Regional complications; pain | Not randomized; no masking; inadequate detail of exclusion criteria; inadequate report of duration of surgery; evaluations not standardized; outcome assessment not objective; analyses not appropriate | 31 | Topical scleral tunnel phacoemulsification was reported as painless, but assessment of pain was not standardized.
Johnston, Whitefield, Giralt et al., 1998 UK | NRT | Claustrophobia, nystagmus. | 82 | To compare topical and peribulbar anesthesia for clear corneal surgery. | Pain | Not randomized; no masking; inadequate description of patient characteristics; inadequate report of duration of surgery; can't tell if evaluationsf standardized | 26 | Topical was a reasonable alternative to peribulbar with clear-cornea phacoemulsification. Avoided pain with block, but some increased discomfort during surgery.
Jolliffe, Abdel-Khalek, and Norton, 1997 UK | RCT | Prior operations, unspecified anesthetic or surgical reasons, anterior chamber lens. | 40 | To compare the effectiveness of topical anesthesia with Van Lint block and retrobulbar block. | Regional complications; pain; patient satisfaction | No masking; inadequate detail of exclusion criteria | 50 | This study suggested that topical anesthesia in combination with lid block was a reasonable alternative to retrobulbar block.
Joyce, Sunderraj, Villada et al., 1994 UK | RCT | None stated. | 169 | To compare the pain of retrobulbar anesthesia with amethocaine cream, EMLA, and placebo. | Akinesia; pain | Inadequate detail of exclusion criteria | 43 | There was no difference between the effectiveness of EMLA versus amethocaine for topical anesthesia prior to retrobulbar block, though both were superior to placebo.
Kaplan, Jaffe, and Clayman, 1985 USA | RCT | None stated. | 194 | To compare different facial blocks and bridle sutures for their effect on postoperative ptosis. | Regional complications | No masking; ancillary treatments not described; inadequate report of duration of surgery; analyses not appropriate | 38 | There was a suggestion that lid block results in a higher incidence of lid ptosis, but many patients were lost to followup.
Kapran, Uyar, Eltutar et al., 1996 Turkey | RCT | Corneal lacerations. | 570 | To compare the effectiveness of sub-Tenon's and retrobulbar anesthesia. | Akinesia; regional complications; pain | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; analyses not appropriate | 25 | Sub-Tenon's appeared less painful than retrobulbar at the time of block and appeared to give slightly better control during surgery.
Kershner, 1993 USA | Case series | | 100 | To evaluate the effectiveness of topical anesthesia. | Supplemental regional; regional complications; pain; patient satisfaction | Not randomized; no masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery; outcome assessment not objective | 23 | Topical anesthesia provided adequate analgesia.
Khoo, Lim, and Yong, 1996 Singapore | RCT | Not reported. | 106 | To compare the effectiveness of sub-Tenon's with retrobulbar anesthesia. | Supplemental regional; regional complications; pain | Ancillary treatments not described; inadequate report of duration of surgery | 46 | Sub-Tenon's anesthesia provided better pain control and equivalent akinesia compared with retrobulbar injection.
Khurana, Sachdeva, Gombar et al., 1994 India | RCT | None stated, consecutive patients. | 200 | To compare the effectiveness of peribulbar with subconjunctival anesthesia. | Regional complications | No masking; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized | 30 | Subconjunctival was less effective than peribulbar in producing akinesia, analgesia, and patient satisfaction.
Kishore, Agarwal, Sood et al., 1990 India | Case series | None stated. | 106 | To describe the effectiveness of a peribulbar anesthetic technique. | Akinesia; regional complications | Not randomized; inadequate detail of exclusion criteria; inadequate description of patient characteristics | 55 | Peribulbar anesthesia was adequate for surgery in 95% of cases.
Koch, 1997 USA | Case series | Patients receiving preoperative sedation for nervousness. | 1,000 | To evaluate the use of intracameral lidocaine for cataract surgery. | Supplemental regional; regional complications | Not randomized; evaluations not standardized; outcome assessment not objective | 54 | Few complications were seen with intracameral lidocaine.
Kollarits, Jaweed, and Kollarits, 1998 USA | NRT | Oral/IV sedation. | 200 | To compare the effectiveness of peribulbar and sub-Tenon's anesthesia. | Akinesia; pain | Not randomized; no masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery; analyses not appropriate | 18 | Patient report of intraoperative and postoperative pain were similar for patients who received peribulbar or sub-Tenon's block.
Kothari, Shah, Shah et al., 1998 India | Case series | None stated, consecutive. | 500 | To evaluate the effectiveness of peribulbar injection supplemented by topical anesthesia. | Akinesia; regional complications; recovery | Not randomized; ancillary treatments not described; inadequate report of duration of surgery; evaluations not standardized | 29 | Single-injection peribulbar block using lidocaine and wydase resulted in good pain control and at least moderate akinesia in most patients.
Krause, Weindler, and Ruprecht, 1997 Germany | RCT | Prior ocular surgery, axial length greater than 26 mm. | 70 | To compare the effectiveness of warmed anesthetic to room temperature anesthetic using a retrobulbar injection. | Akinesia; regional complications; pain; medical complications; sedation complications | Ancillary treatments not described; inadequate report of duration of surgery | 42 | A warmed anesthetic injection solution provided no benefit in akinesia or pain control compared with unwarmed anesthetic solution.
Krohn, Seland, Hovding et al., 1993 Norway | RCT | Patients with ocular comorbidity and contraindications to adrenalin. | 80 | To assess the benefit of hyaluronidase in retrobulbar anesthesia. | Akinesia; supplemental regional; regional complications | Inadequate report of duration of surgery | 46 | The use of hyaluronidase in retrobulbar anesthesia caused a deeper anterior chamber before and after lens extraction and had a reduced incidence of iris prolapse and posterior capsule rupture, but had no impact on akinesia time or need for additional anesthesia.
Lewis, Hamilton, Brant et al., 1992 Canada | RCT | Patients with prior vitreoretinal surgery. | 50 | To assess the effectiveness of the pH adjustment of bupivacaine in peribulbar block. | Akinesia; supplemental regional | Inadequate description of patient characteristics; inadequate report of duration of surgery | 37 | pH adjusted bupivacaine shortened onset time of anesthesia but was associated with a greater need for supplementation. No significant clinical benefits to pH adjustment.
Loots, Koorts, and Venter, 1993 South Africa | NRT | None reported. | 151 | To compare the effectiveness of bupivacaine in two doses and bupivacaine and lidocaine in a combination for peribulbar anaesthesia. | Akinesia; supplemental regional; regional complications; pain | Not randomized; inadequate detail of exclusion criteria; inadequate description of patient characteristics | 45 | Equally poor akinesia and good analgesia for the various combinations.
Maclean, Burton, and Murray, 1997 UK | RCT | Inability to understand VAS. | 50 | To compare peribulbar anesthesia to topical anesthesia supplemented with a small subconjunctival injection. | Regional complications; pain | No masking | 63 | Topical anesthesia was associated with less pain than peribulbar block during administration of anesthesia.
Manners and Burton, 1996 UK | RCT | Prior ocular surgery or injury. | 50 | To compare the effectiveness of topical versus sub-Tenon's local anesthesia. | Pain | No masking; ancillary treatments not described | 44 | Topical and/or sub-Tenon's anesthesia were suited to PE and clear-cornea PE. Sub-Tenon's may be easier for anxious patients or for complicated cases.
Masket and Gokmen, 1998 USA | Cohort | Incomplete chart. | 631 | To study the effect of intracameral lidocaine on patient and surgeon comfort during small-incision surgery. | Regional complications | Not randomized; inadequate description of patient characteristics; inadequate report of duration of surgery | 32 | Intracameral lidocaine was superior to topical anesthesia alone for anesthesia with a slightincrease in corneal edema postoperatively.
Mindel, 1978 USA | RCT | Organic brain disease, pre-existing extraocular muscle paralysis. | 27 | To assess the benefit of hyaluronidase added to 2% mepivicaine for retrobulbar anesthesia. | Akinesia | Inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery | 35 | The addition of hyaluronidase induced akinesia more rapidly with facial and retrobulbar blocks, but the failure rate with hyaluronidase was higher.
Morsman and Holden, 1992 Finland | RCT | None stated, consecutive patients. | 91 | To assess the effectiveness of adrenalin, hyaluronidase, and age on peribulbar anesthesia. | Akinesia; regional complications; pain | No masking; little/no detail of anesthesia: inadequate report of duration of surgery; can't tell if evaluations standardized | 32 | Peribulbar block with hyaluronidase yielded better akinesia and analgesia than peribulbar block without hyaluronidase. There was no benefit from adding adrenalin. Peribulbar block was less effective in patients under age 65.
Muller, Claasen, Schall et al., 1996 South Africa | RCT | None stated. | 100 | To compare the effectiveness of two different bupivacaine hydrochloride products. | Akinesia; supplemental regional; pain | Inadequate detail of exclusion criteria; ancillary treatments not described | 34 | No differences observed.
Murdoch, 1990 UK | RCT | None stated. | 100 | To compare the effectiveness of retrobulbar anesthesia with peribulbar anesthesia. | Akinesia; regional complications; pain | No masking; inadequate report of duration of surgery | 44 | Peribulbar block was less painful and gave better akinesia than retrobulbar block with facial block.
Nathan, Benrhaiem, Lotfi et al., 1996 France | RCT | History of bleeding; cardiac, hepatic, and renal failure. | 20 | To compare the pharmacokinetics of lidocaine and bupivacaine with and without hyaluronidase for peribulbar anesthesia. | Akinesia; regional complications | No masking; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective | 41 | Hyaluronidase may lead to more rapid recovery from akinesia. Hyaluronidase increased the time to peak concentration, but did not increase the actual peak.
Nielsen, 1995 Denmark | NRT | None stated, consecutive. | 56 | To compare visual acuities after retrobulbar and topical anesthesia. | Supplemental regional; regional complications; pain | Not randomized; no masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized | 23 | No difference in acuities but fewer ocular complications in the topical group.
Nielsen and Allerod, 1998 Denmark | RCT | None stated, consecutive patients enrolled. | 130 | To evaluate patient pain and preference with three local anesthesia techniques. | Regional complications; pain; anxiety; patient satisfaction | Inadequate detail of exclusion criteria; can't tell if evaluations standardized | 59 | In this study of bilateral simultaneous cataract surgeries without sedation, retrobulbar, sub-Tenon's, and topical anesthesia were all judged to be satisfactory. Although there was less intraoperative pain with retrobulbar, topical was preferred by some patients because of the discomfort associated with administration of retrobulbar. Almost 50% of patients expressed no preference for one technique over the other.
Nolan, Aziz, Ahmad et al., 1993 Ireland | NRT | None stated, consecutive. | 210 | To compare the effectiveness of seven different block techniques as well as different agents. | Akinesia | Not randomized; no masking; inadequate report of duration of surgery; evaluations not standardized; outcome assessment not objective; analyses not appropriate | 21 | No significant difference between groups.
Ortiz, Blanco, Serra et al., 1995 Spain | RCT | None stated. | 120 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | Akinesia | No masking; inadequate detail of exclusion criteria; ancillary treatments not described; can't tell if evaluations standardized | 28 | Addition of hyaluronidase to peribulbar block with bupivacaine improved akinesia when 5 µl were injected. No difference was found when 9 µl were injected.
Pappa, Pouliou, Nastou et al., 1995 Greece | RCT | None stated. | 33 | To assess the effectiveness of EMLA in reducing pain during local anesthesia delivery. | Akinesia; pain | Inadequate detail of exclusion criteria; inadequate description of patient characteristics; little/no detail of anesthesia | 28 | EMLA cream applied to the skin 1 hour before a local block decreased patient-reported and physician-observed pain during the injection.
Patel, Burns, Crandall et al., 1996 USA | RCT | None stated, consecutive. | 138 | To compare the effectiveness of topical anesthesia with retrobulbar anesthesia. | Regional complications; pain | No masking; can't tell if evaluations standardized | 52 | Patients with topical anesthesia reported slightly more discomfort during administration of anesthesia and postoperatively than did patients receiving retrobulbar block. Overall pain scores were low for both groups.
Patel, Clinch, Burns et al., 1998 USA | RCT | Anticoagulation | 90 | To assess the effectiveness of retrobulbar and topical anesthesia. | Akinesia; supplemental regional; regional complications; pain | No masking; inadequate description of patient characteristics | 49 | Retrobulbar block gave better analgesia and akinesia than topical anesthesia.
Pecka and Dexter, 1997 USA | Case series | 40 missing records. | 560 | To count medical interventions following retrobulbar anesthesia for cataract surgery to estimate the incidence and risk factors. | Akinesia; medical complications; sedation complications | Not randomized | 56 | Interventions were required after the retrobulbar block in 33% of patients who also had IV sedation administered.
Petersen and Yanoff, 1991 USA | Case series | None stated, consecutive. | 385 | To describe a technique of sub-Tenon's anesthesia. | Supplemental regional; regional complications | Not randomized; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; evaluations not standardized; outcome assessment not objective; analyses not appropriate | 9 | Technique reported to be effective; minimal data presented.
Prosser, Rodney, Mian et al., 1996 UK | RCT | Prior anti-coagulant use. | 50 | To assess the effectiveness of hyaluronidase in peribulbar anesthesia. | Akinesia; supplemental regional | Inadequate report of duration of surgery | 56 | Addition of hyaluronidase did not affect the time of onset or rate of obtaining adequate akinesia.
Redmond and Dallas, 1990 UK | Case control | Retrobulbar hemorrhage | 100 | To compare rates of ocular complications for subconjunctival anesthesia with retrobulbar anesthesia. | Regional complications; patient satisfaction | Not randomized; minimal or no detailed exclusion criteria; inadequate description of patient characteristics; little/no detail of anesthesia; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective; analysis not appropriate | 3 | No difference between subconjunctival and retrobulbar anesthesia in rates of operative complications and postoperative visual outcomes.
Roman, Auclin, and Ullern, 1996 France | RCT | None stated. | 90 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | Regional complications; pain; patient satisfaction | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery; analyses not appropriate | 36 | Patients who required cataract surgery on two eyes preferred topical anesthesia over peribulbar block.
Roper and Nisbet, 1978 USA | RCT | Inadequate followup, intercurrent ocular process. | 40 | To assess the effect of hyaluronidase on the incidence of cystoid macular edema. | Regional complications; supplemental regional | Inadequate description of patient characteristics; little/no detail of anesthesia: ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized; analyses not appropriate | 26 | Six cases of cystoid macular edema in group receiving hyaluronidase, none in control group.
Ropo, Ruusuvaara, Paloheimo et al., 1990 Finland | RCT | None stated, consecutive. | 100 | To examine whether ocular compression yields a greater rate of ptosis. | Akinesia, supplemental regional, regional complications, complications of sedation | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery | 37 | No difference in rates of ptosis was observed.
Ruusuvaara, Setala, Pajari et al., 1995 Finland | RCT | None stated. | 112 | To compare the effectiveness of etidocaine with bupivacaine plus lidocaine in retrobulbar anesthesia. | Supplemental regional | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; analyses not appropriate | 16 | Etidocaine produced equivalent akinesia to a combination of lidocaine and bupivacaine; akinesia was longer lasting with etidocaine.
Sanchez-Capuchino, Meadows, and Morgan, 1993 UK | RCT | None stated. | 50 | To compare the effectiveness of retrobulbar anesthesia with and without facial block. | Akinesia; supplemental regional; regional complications; medical complications; sedation complications | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 37 | Lid block conferred no advantage to retrobulbar block alone re: akinesia and lid movement.
Sanders, Ahmed, Craig et al., 1997 UK | RCT | Prior ocular surgery for ophthalmic disease. | 40 | To compare the catecholamine and pressor effects in peribulbar and retrobulbar anesthesia. | Pain | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; analyses not appropriate | 19 | The extra volume of anesthetic required for peribulbar anesthesia did not have adverse effects on serum catecholamines or hemodynamics compared with retrobulbar anesthesia. Intraoperative pain control appeared equivalent in the two groups.
Sarvela, 1993 Finland | RCT | None stated, consecutive patients. | 160 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | Akinesia | | 60 | The high-dose bupivacaine was equivalent to either etidocaine dose for akinesia and superior at achieving analgesia.
Sarvela and Nikki, 1992a Finland | RCT | None stated. | 70 | To assess the effect of hyaluronidase in peribulbar anesthesia. | Akinesia; regional complications | Inadequate description of patient characteristics; evaluations not standardized | 38 | Hyaluronidase added to peribulbar appeared to improve lid akinesia but not globe akinesia or need for intraoperative supplementation.
Sarvela and Nikki, 1992b Finland | RCT | None stated, consecutive patients. | 97 | To compare the effectiveness of a 31mm needle versus a 22mm needle for retrobulbar block with etidocaine. | Akinesia; pain; sedation complications | No masking; inadequate report of duration of surgery | 48 | For peribulbar block, a 31 mm needle was better than a 22mm needle for achieving akinesia and analgesia.
Sarvela, Nikki, and Paloheimo, 1993 Finland | RCT | Muscular or peripheral nerve disease. | 120 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | Akinesia; supplemental regional; regional complications; pain; sedation complications | Inadequate detail of exclusion criteria | 40 | Globe akinesia was similar with and without hyaluronidase and/or epinephrine. Lid block was improved with these agents.
Sarvela, Paloheimo, and Nikki, 1994 Finland | RCT | None stated, consecutive. | 82 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | Akinesia; supplemental regional; regional complications; pain | Inadequate detail of exclusion criteria | 58 | The mixture of lidocaine and bupivacaine conferred better globe akinesia. Both groups were similar with respect to pain during injection and intraoperatively.
Saunders, Sturgess, Pemberton et al., 1993 UK | RCT | None stated. | 85 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | Supplemental regional; regional complications; pain; medical complications | No masking; inadequate detail of exclusion criteria; inadequate report of duration of surgery | 36 | Peribulbar and retrobulbar injection of prilocaine yielded equivalent akinesia and analgesia.
Schimek, Steuhl, and Fahle, 1993 Germany | RCT | Bulbar motility > 2mm 20 minutes after retrobulbar block. | 90 | To compare lidocaine, prilocaine, and mepivicaine for retrobulbar block. | Akinesia | Inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery | 35 | Mepivicaine produced longer anesthesia and akinesia than lidocaine and prilocaine with retrobulbar injection, but all lasted over 3 hours on average.
Scott, Jakeman, Perry et al., 1995 UK | NRT | None stated. | 87 | To compare the effectiveness of a 16mm versus a 25mm needle for peribulbar anesthesia. | Akinesia; regional complications; pain | Not randomized; no masking; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery | 21 | Peribulbar with 16 mm needle may have been slightly more effective than with 25 mm needle.
Shammas, Milkie, and Yeo, 1997 USA | RCT | Age less than 40, small pupil. | 402 | To compare the effectiveness of topical anesthesia with a small injection of subconjunctival anesthesia to retrobulbar anesthesia. | Supplemental regional; regional complications | No masking | 43 | No difference in intraoperative complications or postoperative pain with retrobulbar and subconjunctival injections versus topical and subconjunctival injection. Intraoperative pain was not assessed.
Shibata, Inage, Takayama et al., 1993 Japan | RCT | None stated. | 40 | To assess the use of a cold spray for relieving pain from local injections. | Akinesia | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; little/no detail of anesthesia; ancillary treatments not described; inadequate report of duration of surgery; evaluations not standardized; outcome assessment not objective; analyses not appropriate | 12 | Cold spray prior to injection of retrobulbar anesthesia did not significantly affect the discomfort of the injection but had a small impact on pain from the lid block.
Smith and Kim, 1980 USA | RCT | Known hypersensitivity to amide anesthetics. | 50 | To compare the effectiveness of lidocaine with etidocaine for retrobulbar block. | Supplemental regional | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; little/no detail of anesthesia; inadequate report of duration of surgery; outcome assessment not objective; analyses not appropriate | 19 | Small study with no differences between etidocaine and lidocaine for retrobulbar.
Smith and Smith, 1983 USA | RCT | Extensive medical comorbidity, psychiatric medication use. | 62 | To compare the effectiveness of lidocaine with epinephrine to etidocaine with and without epinephrine for retrobulbar block. | Supplemental regional; regional complications; medical complications | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 55 | Etidocaine produced a longer block with less postoperative pain than lidocaine.
Smith, Kemp, and Smith, 1987 USA | RCT | Drug sensitivity, extensive comorbidity, antidepressant use. | 80 | To compare the effectiveness of retrobulbar block with etidocaine versus a combination of lidocaine and bupivacaine. | Supplemental regional | Inadequate report of duration of surgery | 34 | The mixture of lidocaine and bupivacaine appeared to have longer duration of anesthesia and akinesia than etidocaine and have similar onset of action.
Sunderraj, Kirby, Joyce et al., 1991 UK | RCT | None reported. | 115 | To assess the effectiveness of EMLA in reducing the pain of retrobulbar injection. | Pain | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 42 | Patients had less pain with retrobulbar block when EMLA cream was used.
Suzuki, Kuroki, and Fujiwara, 1997 Japan | NRT | Preexisting ocular disease. | 2,270 | To compare the effect of retrobulbar anesthesia and topical anesthesia on blood pressure. | Regional complications; supplemental regional | Not randomized | 52 | Retrobulbar caused a greater decrease in blood pressure from the start to the end of surgery.
Sweeney, Barber, and Prosser, 1993 Australia | NRT | Not stated, consecutive. | 100 | To compare a transcutaneous and transconjunctival method of periocular anesthesia. | Pain; patient satisfaction | Not randomized; no masking; inadequate description of patient characteristics; inadequate report of duration of surgery; can't tell if evaluations standardized | 32 | Perconjunctival delivery of injection was less painful than percutaneous. However, the percutaneous group also received a lid block.
Thomson, 1988 Ghana | NRT | No exclusions. | 150 | To assess the effectiveness of adding hyaluronidase to lignocaine in retrobulbar block. | Supplemental regional; regional complications | Not randomized; inadequate description of patient characteristics; inadequate report of duration of surgery; evaluations not standardized | 36 | Hyaluronidase in block mixture led to improved akinesia and pain control.
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | NRT | Uncooperative patients. | 45 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | Akinesia; supplemental regional; regional complications | Not randomized; inadequate detail of exclusion criteria | 31 | Etidocaine lasted longer than mepivicaine and they had comparable onset times.
Tseng and Chen, 1998 Taiwan | RCT | Dementia, movement disorder, ocular conditions precluding lid lock. | 162 | To compare the effectiveness of topical lidocaine alone to topical lidocaine with intracameral lidocaine. | Regional complications; pain | Ancillary treatments not described; inadequate report of duration of surgery | 52 | Administration of intracameral lidocaine improved patient comfort intraoperatively when compared to topical anesthesia alone. Both techniques achieved high success rates.
Ursell and Spalton, 1996 UK | RCT | Language or memory impairment. | 40 | To assess the pain associated with peribulbar injection using room temperature and warmed anesthetic agents. | Pain | Not randomized; no masking; analyses not appropriate | 49 | Warmed anesthesia (to body temperature) appeared to cause less discomfort during the injection than when the solution was at room temperature.
Uusitalo, Maunuksela, Paloheimo et al., 1999 Finland | RCT | No exclusions. | 299 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | Supplemental regional; regional complications; pain; patient satisfaction | Not randomized | 58 | Peribulbar had better analgesia than topical, and cataract surgery using topical anesthesia was more difficult; however, acceptable analgesia and surgical conditions were provided by both techniques.
Vettese and Breslin, 1985 Canada | RCT | Not mentioned. | 45 | To compare the effectiveness of three different retrobulbar anesthetic block preparations. | Akinesia; supplemental regional; pain | Inadequate detail of exclusion criteria; inadequate description of patient characteristics; inadequate report of duration of surgery | 31 | The combination of bupivacaine, lidocaine, and epinephrine was more effective at producing lid and globe akinesia than bupivacaine alone or bupivacaine and lidocaine.
Virtanen and Huha, 1998 Finland | RCT | Very hard cataract, previous glaucoma surgery. | 100 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | Akinesia; pain | No masking; inadequate report of duration of surgery | 45 | Pain with topical anesthesia during scleral tunnel ECCE was higher than with peribulbar anesthesia, although it was equal to the pain associated with the peribulbar injection itself.
Waller, Taboada, and O'Connor, 1993 USA | Series | None stated. | 4,000 | To count the globe penetrations in a large consecutive series of retrobulbar anesthesia procedures. | Regional complications | Not randomized; inadequate detail of exclusion criteria; inadequate description of patient characteristics; little/no detail of anesthesia; ancillary treatments not described; can't tell if evaluations standardized | 10 | No globe perforations were seen at institution over 5-year period with over 4,000 retrobulbar injections.
Weiss and Deichman, 1989 USA | RCT | No patients excluded. | 79 | To compare the safety and effectiveness of retrobulbar and periocular anesthesia. | Akinesia; supplemental regional; regional complications; pain; medical complications | Inadequate description of patient characteristics | 56 | No significant difference between retrobulbar and peribulbar blocks in akinesia or anesthesia.
Whitsett, Balyeat, and McClure, 1990 USA | RCT | None stated. | 100 | To compare peribulbar and retrobulbar anesthesia. | Akinesia; supplemental regional; regional complications; medical complications | Inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized; analyses not appropriate | 22 | Regarding lid akinesia, globe akinesia, and ocular anesthesia, the one-injection-site peribulbar block had similar range of effectiveness as the traditional retrobulbar technique.
Wolf, Lynch, and Berlin, 1975 USA | Series | None stated. | 561 | To compare the safety and effectiveness of local versus general anesthesia. | Regional complications | Not randomized; little/no detail of anesthesia: ancillary treatments not described; inadequate report of duration of surgery; can't tell if evaluations standardized; outcome assessment not objective | 12 | Case series described adverse outcomes. No description of the block technique was given. Emphasis is on the safety of general anesthesia.
Wong, Koehrer, Sutton et al., 1993 Canada | RCT | No patients excluded. | 150 | The effectiveness of a superomedial retrobulbar block was compared with an inferolateral retrobulbar block and a peribulbar block. | Akinesia; regional complications; pain; patient satisfaction | Inadequate report of duration of surgery | 65 | Superomedial block yielded better akinesia than inferior retrobulbar or peribulbar and better analgesia than inferior retrobulbar.
Zehetmayer, Radax, Skorpik et al., 1996 Austria | RCT | Diabetes, glaucoma, previous eye surgery, anxious uncooperative patients. | 72 | To compare patient pain and satisfaction with topical anesthesia in one eye and peribulbar anesthesia in the other. | Supplemental regional; regional complications; pain | Inadequate report of duration of surgery | 69 | Topical anesthesia offered superior patient cooperation compared to retrobulbar block, but may have required conversion to retrobulbar block in some patients.
Zehetmayer, Rainer, Turnheim et al., 1997 Austria | RCT | Diabetes, glaucoma, previous eye surgery, uncooperative patients. | 34 | To compare the use of pH-adjusted lidocaine 4% to plain lidocaine 4% for clear-corneal surgery. | Pain | No masking | 57 | pH-adjusted topical lidocaine resulted in significantly higher aqueous humor lidocaine concentrations, but there were no differences in pain control or complications.
(2) Main Topic: Regional Anesthesia and Sedation
Boezaart, Berry, Laubscher et al., 1998 South Africa | RCT | Patient not requesting anxiolytic therapy. | 240 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | Akinesia; regional complications; pain; sedation complications | Inadequate report of duration of surgery | 71 | The use of oral anxiolysis did not have a significant effect on patient anxiety or pain during block placement or surgery.
Cruise, Chung, Yogendran et al., 1997 Canada | RCT | None stated. | 121 | To assess whether intraoperative relaxing music affects satisfaction with surgery. | Patient satisfaction | Inadequate report of duration of surgery | 54 | Relaxing music was associated with greater patient satisfaction than was other noise.
el-Bassiouny, el-Taher, and el-Din, 1992 Egypt | RCT | Patients with severe systemic disease, drug sensitivities, and elevated intraocular pressure. | 40 | To compare alfentanyl and promazine versus meperidine and promazine for sedation. | Pain; patient satisfaction; sedation complications; recovery | Not randomized | 74 | Alfentanyl/promazine provided superior sedation/complication profile compared to meperidine/promazine.
Mjahed, el Harrar, Hamdani et al., 1996 Morocco | RCT | High intraocular pressure, preoperative cardiovascular medication use. | 60 | To compare the effectiveness of retrobulbar block using lidocaine versus lidocaine and clonidine. | Hemodynamics | Inadequate description of patient characteristics | 46 | Clonidine decreased anxiety when added to retrobulbar, but increased the likelihood of bradycardia, hypertension, and sedation.
Wong and Merrick, 1996 Canada | RCT | Patients with dementia, monocular patients, significant pulmonary disease, and use of beta blocker. | 120 | To assess the effectiveness of midazolam, alfentanyl, or both compared with a placebo on pain, recall, and hemodynamics. | Akinesia; pain; patient satisfaction; sedation complications; recovery; hemodynamics | Inadequate report of duration of surgery | 73 | IV sedation offered a small reduction in recall and pain during the block with a slight increase in risk of hypoxemia.
(3) Main Topic: Sedation
Chung, Cheng, Seyone et al., 1990 Canada | RCT | Drug allergy, significant systemic disease, psychotropic medications, impaired mental function. | 60 | To compare the psychomotor recovery of patients sedated with either midazolam or Diazemuls. | Pain; sedation complications; hemodynamics | Inadequate report of duration of surgery | 60 | Midazolam produced better sedation but more prolonged recovery than diazepam.
Coley, Jones, Lassey et al., 1990 UK | RCT | ASA >3, patients with known sensitivity to opioids, Parkinsonism, or markedly increased IOP. | 39 | To compare the hemodynamic effects of alfentanyl and droperidol vs. fentanyl and droperidol. | Akinesia; sedation complications; recovery | Not randomized | 71 | The combination of alfentanyl/droperidol with diazepam premedication offered a safe analgesic regimen.
Cugini, Lanzetta, Nadbath et al., 1997 Italy | RCT | Age <65, ocular surgery, or medications. | 80 | To assess the effectiveness of ketamine for sedation and pain control. | Recovery | No masking; inadequate report of duration of surgery; analyses not appropriate | 41 | Ketamine, when used in conjunction with diazepam + droperidol, significantly decreased pain during placement of block, as well as preventing a significant decrease in systolic BP after sedation was given.
Filos, Patroni, Goudas et al., 1993 Greece | RCT | Recent MI, ischemic EKG charges, diastolic BP >100mm Hg, ocular comorbidity. | 60 | To compare the hemodynamics profile of two doses of oral clonidine premedication. | Sedation complications | Ancillary treatments not described; inadequate report of duration of surgery | 63 | Clonidine (at intermediate dose 0.15 mg) was associated with sedation and superior hemodynamics.
Gilbert, Holt, Johnston et al., 1987 USA | RCT | Individuals with sensitivity to study drugs, a history of hepatic or renal disease, and those receiving psychotic, psychotropic, or narcotic drugs. | 55 | To compare the effectiveness of nalbuphine and methohexital one versus fentanyl and diazepam. | Pain; patient satisfaction; sedation complications; recovery; hemodynamics | Not randomized | 67 | Combination of nalbuphine/methohexital one was superior to fentanyl/diazepam for operating conditions.
Herrick, Gelb, Nichols et al., 1996 Canada | RCT | None stated. | 55 | To assess the effectiveness of patient controlled sedation with propofol. | Supplemental regional; regional complications; medical complications; sedation complications; hemodynamics | No masking | 61 | The presence of a PCS system with propofol significantly improved patients' overall satisfaction with the procedure, even if the PCS was not used.
Ibrahim and Savino, 1974 USA | RCT | All patients involved. | 67 | To compare effectiveness of IV valium with a combination of meperidine, phenobarbital, and promethazine for sedation. | Pain; anxiety; sedation complications | Inadequate description of patient characteristics; can't tell if evaluations standardized; analyses not appropriate | 50 | No difference in pain, anxiety, hemodynamics, or patient cooperation for diazepam >= 10 mg IV versus a combination of phenergan, demerol, and phenobarbital.
Karhunen and Orko, 1981 Finland | RCT | None stated. | 150 | To compare the rates of postoperative nausea and vomiting using pethidine alone or pethidine with droperidol. | Akinesia pain; sedation complications; recovery | No masking; inadequate detail of exclusion criteria | 34 | No significant difference in postoperative nausea/vomiting between groups who received regional anesthesia with or without droperidol.
Khalil, Howard, Mankarious et al., 1998 USA | RCT | None stated. | 60 | To compare alfentanyl to lidocaine IV for reducing patient response to retrobulbar block. | Sedation complications; recovery; hemodynamics | Inadequate detail of exclusion criteria; inadequate report of duration of surgery | 61 | Alfentanyl 5mg/kg IV significantly decreased myoclonus and cough associated with methohexital injection (1.5mg/kg IV) versus lidocaine or placebo. Alfentanyl 5mg/kg IV significantly attenuated hemodynamic responses to retrobulbar block placement.
Kost and Emerson, 1992 USA | RCT | Mental retardation, ASA of 4 or greater. | 74 | To compare propofol and fentanyl versus midazolam and fentanyl for sedation. | Pain; patient satisfaction; recovery | No masking; inadequate report of duration of surgery; analyses not appropriate | 48 | Propofol/fentanyl were associated with better patient satisfaction, lower incidence of 0_2_ desaturation, and lack of recall compared to midazolam/fentanyl.
Kumar, Bose, Bhattacharya et al., 1992 India | RCT | ASA of 3 or greater. | 100 | To compare oral clonidine with oral diazepam for sedation and hemodynamics. | Recovery | Can't tell if evaluations standardized | 65 | Oral clonidine (300mg) was superior to oral diazepam (0.15mg/kg) as an anxiolytic. Clonidine also showed a superior effect on hemodynamic stability as compared to oral diazepam.
Kumar, Tandon, Bhattacharya et al., 1994 Indiam | RCT | Patients receiving clonidine, beta-blocker, or calcium channel blockers. | 34 | To compare anesthetic recovery with inpatients receiving oral clonidine or oral diazepam before surgery. | Pain; anxiety | Not randomized | 65 | Diazepam resulted in prolonged recovery compared to clonidine.
Michelson and Naujoks, 1991 Germany | RCT | None stated. | 31 | To compare respiratory function with and without supplemental 0_2_ administration during cataract surgery. | Akinesia; hemodynamics | No masking; inadequate detail of exclusion criteria; inadequate report of duration of surgery | 37 | Even in the absence of sedation, oxygen saturation may have decreased below 90% and supplementation by nasal cannula was of benefit.
Oikkonen, 1994 Finland | RCT | None stated, consecutive. | 100 | To compare oral melperon with oral diazepam for sedation. | Akinesia; sedation complications; recovery; hemodynamics | Little/no detail of anesthesia | 51 | Melperon offered favorable antianxiety effects but was associated with hypotension.
Oikkonen, Heine, Salminen et al., 1994 Finland | RCT | Psychiatric medications or illnesses, age >70. | 100 | To compare oral dixyrazine with oral diazepam for sedation. | Pain; anxiety | | 60 | Dixyrazine, a neuroleptic, offered a similar antianxiety effect to diazepam.
Oikkonen and Reinikainen, 1996 Finland | RCT | Digitalis medication, arrhythmias. | 33 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen in saturation during cataract surgery. | Medical complications; sedation complications; hemodynamics | No masking; inadequate report of duration of surgery | 62 | Supplemental oxygen in patients with heart disease decreased incidence of myocardial ischemia.
Pac-Soo, Deacock, Lockwood et al., 1996 UK | RCT | Age >85, cardiopulmonary disease. | 49 | To compare self-administered midazolam or propofol with saline for sedation and hemodynamic effect. | Supplemental regional; regional complications; pain; sedation complications; hemodynamics | Not randomized | 63 | The availability of patient-controlled sedation with either midazolam or propofol significantly reduced anxiety during cataract surgery, whether or not the drugs were used. Midazolam PCS significantly prevented increases in systolic BP versus propofol.
Rosenberg, Raymond, and Bridge, 1995 USA | RCT | None stated. | 40 | To compare the effectiveness of midazolam and ketamine versus methohexital for sedation during peribulbar block. | Pain; sedation complications; recovery; hemodynamics | No masking; inadequate detail of exclusion criteria; inadequate description of patient characteristics; ancillary treatments not described; inadequate report of duration of surgery | 27 | Low-dose midazolam/ketamine sedation was superior to methohexital sedation regarding patient movement and respiratory depression/obstruction.
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | RCT | Neuropsychiatric medications. | 90 | To compare IM alfentanyl with IM midazolam for sedation. | Regional complications; pain; medical complications; sedation complications; recovery; hemodynamics | Not randomized | 76 | Alfentanyl IM was superior to IM midazolam and placebo regarding reduction of pain during regional block placement. Both alfentanyl IM and midazolam IM were superior to placebo in providing anxiolysis and adequate sedation for cataract surgery.
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | RCT | None stated. | 35 | To assess the sedative and hemodynamic effects of different doses of IM dexmedetomidine. | Hemodynamics | Inadequate detail of exclusion criteria | 64 | Dexmedetomidine did not provide statistically significant sedation or anxiolysis compared to placebo.
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | RCT | None stated. | 90 | To assess the sedative and hemodynamic effects of dexmedetomidine and midazolam. | Recovery; hemodynamics | Not randomized; analyses not appropriate | 62 | IM dexmedetomidine, an alpha-2-blocker, was equally effective as IM midazolam for sedation, anxiolysis, and nausea/vomiting. Both gave better sedation and anxiolysis than placebo.
Yee, Burns, Mann et al., 1996 USA | RCT | None stated. | 30 | To compare propofol alone to combinations of propofol and alfentanyl for sedation and patient comfort and adverse outcomes. | Akinesia; supplemental regional; regional complications; pain; medical complications; sedation complications; recovery; hemodynamics | No masking; inadequate detail of exclusion criteria; inadequate report of duration of surgery | 44 | Alfentanyl 10 mg/kg IV combined with propofol 0.25 mg/kg IV provided the best limitation of patient movement while maintaining safe hemodynamic parameters during retrobulbar block placement, as compared to propofol alone, propofol and 5 mg/kg alfentanyl, or propofol 15 mg/kg IV.
Yee, Schafer, Crandall et al., 1994 USA | RCT | None stated. | 30 | To compare the effectiveness of methohexital and alfentanyl on movement during retrobulbar block. | Akinesia; sedation complications; recovery; hemodynamics | Inadequate detail of exclusion criteria; ancillary treatments not described; inadequate report of duration of surgery | 54 | Alfentanyl resulted in less movement during the block without increased risk of respiratory depression.

Evidence Table 2. Summary of interventions reported in literature on anesthesia for cataract surgery

Author(s) year, and country of study | Group | Description of block: Block type Needle length Needle gauge Needle type | Agent(s) | Additional agents or techniques | Volume/drops location | Facial/lid block? | Catract removal technique | Mean surgical time | Sedation
Main Topic: Regional Anesthesia
Abelson, Mandel, Paradis et al., 1989 USA | 1 | Retrobulbar 1.25 inches Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | None planned
Abelson, Mandel, Paradis et al., 1989 USA | 1 | Retrobulbar 1.25 inches Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | None planned
Abelson, Mandel, Paradis et al., 1989 USA | 2 | Retrobulbar 1.25 inches Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | No | Can't tell | | None planned
Abelson, Mandel, Paradis et al., 1989 USA | 2 | Retrobulbar 1.25 inches Can't tell Not specified | Lidocaine | | <4 cc Can't tell | No | Can't tell | | None planned
Agrawal and Athanikar, 1994 India | 1 | Peribulbar 15 mm Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | ECCE | | None planned
Agrawal and Athanikar, 1994 India | 1 | Peribulbar 15 mm Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Superotemporal | No | ECCE | | None planned
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 1 | Retrobulbar 30 mm 23 Sharp | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 1 | Retrobulbar 30 mm 23 Sharp | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 2 | Peribulbar 25 mm 24 Sharp | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Superomedial | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 2 | Peribulbar 25 mm 24 Sharp | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 2 | Peribulbar 25 mm 24 Sharp | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 2 | Peribulbar 25 mm 24 Sharp | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Superomedial | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 3 | Peribulbar 25 mm 24 Sharp | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 3 | Peribulbar 25 mm 24 Sharp | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 3 | Peribulbar 25 mm 24 Sharp | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | 3 | Peribulbar 25 mm 24 Sharp | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | Yes | Can't tell | | Oral
Anderson, 1995 USA | 1 | Subconjunctival | Bupivacaine | Hyaluronidase | <4 cc | No | PE | | IV benzodiazepines
Anderson, 1995 USA | 1 | Subconjunctival | Lidocaine | Hyaluronidase | <4 cc | No | PE | | IV benzodiazepines
Anderson, Nath, and Anderson, 1999 USA | 1 | Topical | Proparacaine Lidocaine Intracameral lidocaine | | 1 4 | No | PE clear cornea | 12 | IV benzodiazepines
Anderson, Nath, and Anderson, 1999 USA | 2 | Topical | Proparacaine Lidocaine | | 1 4 | No | PE clear cornea | 13 | IV benzodiazepines
Athanikar and Agrawal, 1991 India | 1 | Retrobulbar 37.5 mm 23 Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | ECCE | | None planned
Athanikar and Agrawal, 1991 India | 2 | Peribulbar 15 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | ECCE | | None planned
Bell and Butt, 1995 UK | 1 | Peribulbar 25 mm 25 Sharp | Lidocaine | Hyaluronidase Anesthesia warming | >6 cc Inferomedial | Can't tell | ECCE | | None planned
Bell and Butt, 1995 UK | 2 | Peribulbar 25 mm 25 Sharp | Lidocaine | Hyaluronidase | >6 cc Inferomedial | Can't tell | ECCE | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 1 | Peribulbar 25 mm 24 Sharp | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | No | Can't tell | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 1 | Peribulbar 25 mm 24 Sharp | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 1 | Peribulbar 25 mm 24 Sharp | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | No | Can't tell | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 1 | Peribulbar 25 mm 24 Sharp | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 2 | Peribulbar 25 mm 24 Sharp | Lidocaine | | <4 cc Inferotemporal | No | Can't tell | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 2 | Peribulbar 25 mm 24 Sharp | Lidocaine | | <4 cc Inferomedial | No | Can't tell | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 2 | Peribulbar 25 mm 24 Sharp | Bupivacaine | | <4 cc Inferotemporal | No | Can't tell | | None planned
Bjornstrom, Hansen, Otland et al., 1994 Denmark | 2 | Peribulbar 25 mm 24 Sharp | Bupivacaine | | <4 cc Inferomedial | No | Can't tell | | None planned
Briggs, Beck, and Esakowitz, 1997 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | Can't tell Can't tell | No | Can't tell | | None planned
Briggs, Beck, and Esakowitz, 1997 UK | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | Can't tell Can't tell | No | Can't tell | | None planned
Briggs, Beck, and Esakowitz, 1997 UK | 2 | Subconjunctival | Bupivacaine | Hyaluronidase | | No | Can't tell | | None planned
Buttery and Wise, 1989 Australia | 1 | Retrobulbar Can't tell Can't tell Can't tell | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | 24 | Oral
Buttery and Wise, 1989 Australia | 2 | Retrobulbar 50 25 Sharp | Lidocaine | Hyaluronidase | <4 cc Transconjunctival | Yes | Can't tell | 27 | Oral
Carino, Slomovic, Chung et al., 1998 Canada | 1 | Topical | Tetracaine | | 4 | No | PE clear cornea | | None planned
Carino, Slomovic, Chung et al., 1998 Canada | 2 | Topical | Tetracaine | | 4 | No | PE clear cornea | | None planned
Chittenden, Meacock, and Govan, 1997 UK | 1 | Subconjunctival Topical | Lidocaine Oxybuprocaine | Epinephrine | <4 cc | No | PE | | None planned
Chittenden, Meacock, and Govan, 1997 UK | 2 | Topical | Oxybuprocaine | | | No | PE | | None planned
Corboy and Jiang, 1997 USA | 1 | Retrobulbar 1.5 mm 25 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | PE | | None planned
Crandall, Zabriskie, Patel et al., 1999 USA | 1 | Topical | Bupivacaine | | 6 | No | PE clear cornea | | None planned
Crandall, Zabriskie, Patel et al., 1999 USA | 2 | Topical | Bupivacaine | | 6 | No | PE clear cornea | | None planned
Davis and Mandel, 1986 USA | 1 | Peribulbar 1.25 inches 23g Blunt | Lidocaine | Hyaluronidase | 4-6 cc Inferomedial | Yes | Can't tell | | None planned
Davis and Mandel, 1986 USA | 1 | Peribulbar 1.25 inches 23g Blunt | Lidocaine | Hyaluronidase | 4-6 cc Superomedial | Yes | Can't tell | | None planned
Davis and Mandel, 1986 USA | 1 | Peribulbar 1.25 inches 23g Blunt | Bupivacaine | Hyaluronidase | 4-6 cc Inferomedial | Yes | Can't tell | | None planned
Davis and Mandel, 1986 USA | 1 | Peribulbar 1.25 inches 23g Blunt | Bupivacaine | Hyaluronidase | 4-6 cc Superomedial | Yes | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 1 | Subconjunctival | Lidocaine | Hyaluronidase | <4 cc | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 1 | Peribulbar 36 mm 25 Not specified | Lidocaine | Hyaluronidase | >6 cc Superomedial | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 1 | Peribulbar 36 mm 25 Not specified | Lidocaine | Hyaluronidase | >6 cc Superotemporal | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 1 | Peribulbar 36 mm 25 Not specified | Lidocaine | Hyaluronidase | >6 cc Inferomedial | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Subconjunctival 25 | Lidocaine | Hyaluronidase | <4 cc | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Subconjunctival 25 | Bupivacaine | Hyaluronidase | <4 cc | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Peribulbar 36 mm 25 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Inferomedial | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Peribulbar 36 mm 25 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Peribulbar 36 mm 25 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Superotemporal | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Peribulbar 36 mm 25 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Inferomedial | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Peribulbar 36 mm 25 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Superotemporal | No | Can't tell | | None planned
Davis and O'Connor, 1989 Canada | 2 | Peribulbar 36 mm 25 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | None planned
Demirok, Simsek, Cinal et al., 1997 Turkey | 1 | Peribulbar 22 mm 25 Blunt | Lidocaine | Hyaluronidase Slow injection Anesthesia warming | <4 cc Inferotemporal | No | Can't tell | | None planned
Demirok, Simsek, Cinal et al., 1997 Turkey | 1 | Peribulbar 22 mm 25 Blunt | Bupivacaine | Hyaluronidase Slow injection Anesthesia warming | <4 cc Inferotemporal | No | Can't tell | | None planned
Demirok, Simsek, Cinal et al., 1997 Turkey | 2 | Peribulbar 22 mm 25 Blunt | Bupivacaine | Hyaluronidase Slow injection | <4 cc Superomedial | No | Can't tell | | None planned
Demirok, Simsek, Cinal et al., 1997 Turkey | 2 | Peribulbar 22 mm 25 Blunt | Bupivacaine | Hyaluronidase Slow injection | <4 cc Inferotemporal | No | Can't tell | | None planned
Demirok, Simsek, Cinal et al., 1997 Turkey | 2 | Peribulbar 22 mm 25 Blunt | Lidocaine | Hyaluronidase Slow injection | <4 cc Superomedial | No | Can't tell | | None planned
Demirok, Simsek, Cinal et al., 1997 Turkey | 2 | Peribulbar 22 mm 25 Blunt | Lidocaine | Hyaluronidase Slow injection | <4 cc Inferotemporal | No | Can't tell | | None planned
Dinsmore, 1995 USA | 1 | Topical | Lidocaine | | 12 | No | PE | | None planned
Dinsmore, 1996 USA | 1 | Topical | Lidocaine | | 12 | No | PE clear cornea | | IV benzodiazepines IV analgesics
Dopfmer, Maloney, Gaynor et al.,1996 Germany | 1 | Peribulbar 25 mm 25 Sharp | Lidocaine | Hyaluronidase Epinephrine Felypressin | 4-6 cc Inferomedial | No | Can't tell | | None planned
Dopfmer, Maloney, Gaynor et al.,1996 Germany | 1 | Peribulbar 25 mm 25 Sharp | Bupivacaine | Hyaluronidase Epinephrine Felypressin | 4-6 cc Inferomedial | No | Can't tell | | None planned
Dopfmer, Maloney, Gaynor et al.,1996 Germany | 2 | Peribulbar 25 mm 25 Sharp | Prilocaine | Hyaluronidase Felypressin | >6 cc Inferomedial | No | Can't tell | | None planned
Edge, McClarty, Krige et al., 1995 Saudi Arabia | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | Can't tell Can't tell | Yes | Can't tell | | None planned
Edge, McClarty, Krige et al., 1995 Saudi Arabia | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | Can't tell Can't tell | Yes | Can't tell | | None planned
Edge, McClarty, Krige et al., 1995 Saudi Arabia | 2 | Peribulbar 38 mm 25 Not specified | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | | None planned
Edge, McClarty, Krige et al., 1995 Saudi Arabia | 2 | Peribulbar 38 mm 25 Not specified | Bupivacaine | Hyaluronidase | <4 cc Superomedial | No | Can't tell | | None planned
Edge, McClarty, Krige et al., 1995 Saudi Arabia | 2 | Peribulbar 38 mm 25 Not specified | Lidocaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | | None planned
Edge, McClarty, Krige et al., 1995 Saudi Arabia | 2 | Peribulbar 38 mm 25 Not specified | Lidocaine | Hyaluronidase | <4 cc Superomedial | No | Can't tell | | None planned
Ellingsson and Aasved, 1979 Norway | 1 | Retrobulbar 30 mm Can't tell Blunt | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Transconjunctival | Yes | Can't tell | | IV benzodiazepines
Ellingsson and Aasved, 1979 Norway | 2 | Retrobulbar 30 mm Can't tell Blunt | Etidocaine | Hyaluronidase | 4-6 cc Transconjunctival | Yes | Can't tell | | IV benzodiazepines
Ellingsson and Aasved, 1979 Norway | 3 | Retrobulbar 30 mm Can't tell Blunt | Etidocaine | Hyaluronidase Epinephrine | 4-6 cc Transconjunctival | Yes | Can't tell | | IV benzodiazepines
Feibel, Custer, and Gordon, 1993 USA | 1 | Peribulbar 1.5 inches 23 Not specified | Mepivicaine | Hyaluronidase | 4-6 cc Superomedial | Yes | Can't tell | | None planned
Feibel, Custer, and Gordon, 1993 USA | 1 | Peribulbar 1.5 inches 23 Not specified | Mepivicaine | Hyaluronidase | 4-6 cc Inferotemporal | Yes | Can't tell | | None planned
Feibel, Custer, and Gordon, 1993 USA | 1 | Peribulbar 1.5 inches 23 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Superomedial | Yes | Can't tell | | None planned
Feibel, Custer, and Gordon, 1993 USA | 1 | Peribulbar 1.5 inches 23 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Inferotemporal | Yes | Can't tell | | None planned
Feibel, Custer, and Gordon, 1993 USA | 2 | Retrobulbar 1.5 inches 23 Not specified | Mepivicaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | None planned
Feibel, Custer, and Gordon, 1993 USA | 2 | Retrobulbar 1.5 inches 23 Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | None planned
Fukasaku and Marron, 1994 Japan | 1 | Retrobulba No details Topical | Lidocaine | | Can't tell | No | PE | | None planned
Fukasaku and Marron, 1994 Japan | 2 | Subconjunctival 27 Topical | Lidocaine Lidocaine | | <4 cc | No | PE | | None planned
Fukasaku and Marron, 1994 Japan | 3 | Subconjunctival 24 Topical | Lidocaine Lidocaine | | <4 cc | No | PE | | None planned
Fukasaku and Marron, 1994 Japan | 4 | Topical | Lidocaine | | | No | PE | | None planned
Fukasaku and Marron, 1994 Japan | 5 | Topical | Lidocaine | | | No | PE | | None planned
Furuta, Toriumi, Kashiwagi et al., 1990 Japan | 1 | Subconjunctival | Lidocaine | Epinephrine | <4 cc | | Can't tell | 30 | No details
Garcia, Loureiro, Limao et al., 1998 Portugal | 1 | Topical | Tetracaine | | | No | PE | | None planned
Garcia, Loureiro, Limao et al., 1998 Portugal | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | No | PE | | None planned
Garcia, Loureiro, Limao et al., 1998 Portugal | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | No | PE | | None planned
Gillart, Bazin, Deret et al., 1996 France | 1 | Peribulbar 25 25 | Bupivacaine | Hyaluronidase Slow injection Low injection pressure | 4-6 cc Superotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 1 | Peribulbar 25 25 | Bupivacaine | Hyaluronidase Slow injection Low injection pressure | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 1 | Peribulbar 25 25 | Bupivacaine | Hyaluronidase Slow injection Low injection pressure | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 1 | Peribulbar 25 25 | Etidocaine | Hyaluronidase Slow injection Low injection pressure | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 1 | Peribulbar 25 25 | Etidocaine | Hyaluronidase Slow injection Low injection pressure | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 1 | Peribulbar 25 25 | Etidocaine | Hyaluronidase Slow injection Low injection pressure | 4-6 cc Superotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 2 | Peribulbar 25 25 | Bupivacaine | Hyaluronidase Fast injection High injection pressure | 4-6 cc Superotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 2 | Peribulbar 25 25 | Bupivacaine | Hyaluronidase Fast injection High injection pressure | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 2 | Peribulbar 25 25 | Bupivacaine | Hyaluronidase Fast injection High injection pressure | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 2 | Peribulbar 25 25 | Etidocaine | Hyaluronidase Fast injection High injection pressure | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 2 | Peribulbar 25 25 | Etidocaine | Hyaluronidase Fast injection High injection pressure | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Deret et al., 1996 France | 2 | Peribulbar 25 25 | Etidocaine | Hyaluronidase Fast injection High injection pressure | 4-6 cc Superotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 1 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Slow injection | <4 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 1 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Slow injection | <4 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 1 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Slow injection | <4 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 1 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Slow injection | <4 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 2 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Fast injection | <4 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 2 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Fast injection | <4 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 2 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Fast injection | <4 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 2 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Fast injection | <4 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 3 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Slow injection | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 3 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Slow injection | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 3 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Slow injection | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 3 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Slow injection | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 4 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Fast injection | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 4 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Fast injection | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 4 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Fast injection | 4-6 cc Inferotemporal | No | Can't tell | | IV propofol
Gillart, Bazin, Montetagaud et al., 1998 France | 4 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Fast injection | 4-6 cc Superomedial | No | Can't tell | | IV propofol
Gills, Cherchio, and Raanan, 1997 USA | 1 | Topical Intracameral Lidocaine | Proparacaine Bupivacaine | | 2 4 | No | PE | | None planned
Gills, Cherchio, and Raanan, 1997 USA | 2 | Topical | Proparacaine Bupivacaine | | 2 4 | No | PE | | None planned
Guise, 1996 New Zealand | 1 | Subconjunctival | Bupivacaine | Hyaluronidase | <4 cc | Yes | Can't tell | | None planned
Gutman, Sinskey, and Cain, 1979 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | Yes | Can't tell | | No details
Gutman, Sinskey, and Cain, 1979 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | Yes | Can't tell | | No details
Hamilton and Claoue, 1998 UK | 1 | Topical | Proparacaine | | 2 | No | PE clear cornea | | None planned
Hamilton and Claoue, 1998 UK | 2 | Topical | Tetracaine | | 2 | No | PE clear cornea | | None planned
Hamilton, Gimbel, and Strunin, 1988 Canada | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | <4 cc Inferotemporal | Yes | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | <4 cc Inferotemporal | Yes | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | 4-6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | 4-6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 3 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 3 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 3 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Superomedial | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 3 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Superomedial | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 4 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 4 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Superomedial | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 4 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 4 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Superomedial | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 5 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Superomedial | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 5 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 5 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Inferotemporal | No | Can't tell | | No details
Hamilton, Gimbel, and Strunin, 1988 Canada | 5 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine Anesthesia warming | >6 cc Superomedial | No | Can't tell | | No details
Henderson and Franks, 1996 UK | 1 | Peribulbar 25 mm 25 Not specified | Prilocaine | Hyaluronidase | 4-6 cc Inferotemporal | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 1 | Peribulbar 25 mm 25 Not specified | Prilocaine | Hyaluronidase | 4-6 cc Transconjunctival | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 1 | Peribulbar 25 mm 25 Not specified | Prilocaine | Hyaluronidase | 4-6 cc Inferomedial | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Transconjunctival | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | No | Can't tell | 35 | None planned
Henderson and Franks, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Transconjunctival | No | Can't tell | 35 | None planned
Hendrick, Rosenberg, and Lebenbom-Mansour, 1997 USA | 1 | Peribulbar 1.0 inches 25 Sharp | Bupivacaine | Hyaluronidase pH buffering | <4 cc Inferotemporal | No | Can't tell | 35 | IV benzodiazepines
Hendrick, Rosenberg, and Lebenbom-Mansour, 1997 USA | 1 | Peribulbar 1.0 inches 25 Sharp | Lidocaine | Hyaluronidase pH buffering | <4 cc Inferotemporal | No | Can't tell | 35 | IV benzodiazepines
Hinshaw, Fiscella, and Sugar, 1995 USA | 1 | Retrobulbar 23g | Lidocaine | Hyaluronidase pH buffering | >6 cc Can't tell | Yes | Can't tell | | Oral
Hinshaw, Fiscella, and Sugar, 1995 USA | 1 | Retrobulbar 23g | Bupivacaine | Hyaluronidase pH buffering | >6 cc Can't tell | Yes | Can't tell | | Oral
Hinshaw, Fiscella, and Sugar, 1995 USA | 2 | Retrobulbar 23g | Bupivacaine | Hyaluronidase | >6 cc Can't tell | Yes | Can't tell | | Oral
Hinshaw, Fiscella, and Sugar, 1995 USA | 2 | Retrobulbar 23g | Lidocaine | Hyaluronidase | >6 cc Can't tell | Yes | Can't tell | | Oral
Hodgkins, Teye-Botchway, Morrell et al., 1992 UK | 1 | Topical | Amethocaine | | | Yes | ECCE | | IV analgesics IV other
Hosal, Tekeli, and Gursel, 1998 Turkey | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Epinephrine | <4 cc Can't tell | Yes | ECCE | | None planned
House, Hollands, and Schulzer, 1991 Canada | 1 | Peribulbar 38 mm 25 Sharp | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 1 | Peribulbar 38 mm 25 Sharp | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 1 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 1 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 2 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase Epinephrine | >6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 2 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase Epinephrine | >6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 3 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 3 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Epinephrine | 4-6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 3 | Peribulbar 38 mm 25 Sharp | Lidocaine | Epinephrine | 4-6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 3 | Peribulbar 38 mm 25 Sharp | Lidocaine | Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 4 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase | >6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 4 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase | >6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 5 | Peribulbar 38 mm 25 Sharp | Bupivacaine | | >6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 5 | Peribulbar 38 mm 25 Sharp | Bupivacaine | | >6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 6 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Epinephrine | >6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 6 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Epinephrine | >6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 7 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase | 4-6 cc Inferotemporal | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 7 | Peribulbar 38 mm 25 Sharp | Bupivacaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 7 | Peribulbar 38 mm 25 Sharp | Lidocaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | Oral
House, Hollands, and Schulzer, 1991 Canada | 7 | Peribulbar 38 mm 25 Sharp | Lidocaine | Hyaluronidase | 4-6 cc Inferotemporal | No | Can't tell | | Oral
Huha, Ala-Kokko, Salomaki et al., 1999 Finland | 1 | Peribulbar 25 mm 25 Sharp | Bupivacaine | Hyaluronidase | >6 cc Superomedial | No | Can't tell | | None planned
Huha, Ala-Kokko, Salomaki et al., 1999 Finland | 1 | Peribulbar 25 mm 25 Sharp | Bupivacaine | Hyaluronidase | >6 cc Transconjunctival | No | Can't tell | | None planned
Huha, Ala-Kokko, Salomaki et al., 1999 Finland | 2 | Peribulbar 25 mm 25 Sharp | Ropivicaine | Hyaluronidase | >6cc Superomedial | No | Can't tell | | None planned
Huha, Ala-Kokko, Salomaki et al., 1999 Finland | 2 | Peribulbar 25 mm 25 Sharp | Ropivicane | Hyaluronidase | >6cc Transconjunctival | No | Can't tell | | None planned
Johansen, Kjeldgard, and Corydon, 1993 Denmark | 1 | Retrobulbar 40 mm 27 (0.4 mm) Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | | None planned
Johansen, Kjeldgard, and Corydon, 1993 Denmark | 1 | Retrobulbar 40 mm 27 (0.4 mm) Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | | None planned
Johansen, Kjeldgard, and Corydon, 1993 Denmark | 2 | Retrobulbar 40 mm 27 (0.4 mm) Not specified | Bupivacaine | Epinephrine | <4 cc Inferotemporal | No | Can't tell | | None planned
Johansen, Kjeldgard, and Corydon, 1993 Denmark | 2 | Retrobulbar 40 mm 27 (0.4 mm) Not specified | Lidocaine | Epinephrine | <4 cc Inferotemporal | No | Can't tell | | None planned
Johansen, Kjeldgard, and Corydon, 1993 Denmark | 3 | Retrobulbar 40 mm 27 (0.4 mm) Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Johansen, Kjeldgard, and Corydon, 1993 Denmark | 4 | Retrobulbar 40 mm 27 (0.4 mm) Not specified | Lidocaine | Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | None planned
John, 1998 USA | 1 | Topical | Proparacaine | | | No | PE | | IV benzodiazepines IV propofol
John, 1998 USA | 2 | Topical | Lidocaine | | | No | PE | | IV benzodiazepines IV propofol
Johnston, Whitefield, Giralt et al., 1998 UK | 1 | Topical | Amethocaine | 4 | No | PE clear cornea | | None planned
Johnston, Whitefield, Giralt et al., 1998 UK | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Transconjunctival | No | PE clear cornea | | None planned
Johnston, Whitefield, Giralt et al., 1998 UK | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Transconjunctival | No | PE clear cornea | | None planned
Jolliffe, Abdel-Khalek, and Norton, 1997 UK | 1 | Topical | Lidocaine | | | Yes | Can't tell | | Oral
Jolliffe, Abdel-Khalek, and Norton, 1997 UK | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | Oral
Jolliffe, Abdel-Khalek, and Norton, 1997 UK | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | Oral
Joyce, Sunderraj, Villada et al., 1994 UK | 1 | Retrobulbar 30 mm 23 Not specified | Bupivacaine | Hyaluronidase Amethocaine cream | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Joyce, Sunderraj, Villada et al., 1994 UK | 2 | Retrobulbar 30 mm 23 Not specified | Bupivacaine | Hyaluronidase EMLA cream | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Joyce, Sunderraj, Villada et al., 1994 UK | 3 | Retrobulbar 30 mm 23 Not specified | Bupivacaine | Hyaluronidase Placebo cream | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Kaplan, Jaffe, and Clayman, 1985 USA | 1 | Retrobulbar 1.5 inches 22 Not specified | Xyolocaine | Hyaluronidase Epinephrine | Can't tell Inferotemporal | Yes | PE | | None planned
Kaplan, Jaffe, and Clayman, 1985 USA | 2 | Retrobulbar 1.5 inches 22 Not specified | Xyolocaine | Hyaluronidase Epinephrine | Can't tell Inferotemporal | Yes | PE | | None planned
Kaplan, Jaffe, and Clayman, 1985 USA | 3 | Retrobulbar 1.5 inches 22 Not specified | Xyolocaine | Hyaluronidase Epinephrine | Can't tell Inferotemporal | Yes | PE | | None planned
Kaplan, Jaffe, and Clayman, 1985 USA | 4 | Retrobulbar 1.5 inches 22 Not specified | Xyolocaine | Hyaluronidase Epinephrine | Can't tell Inferotemporal | Yes | PE | | None planned
Kapran, Uyar, Eltutar et al., 1996 Turkey | 1 | Retrobulbar 35 mm 23 Sharp | Lidocaine | | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Kapran, Uyar, Eltutar et al., 1996 Turkey | 1 | Retrobulbar 35 mm 23 Sharp | Bupivacaine | | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Kapran, Uyar, Eltutar et al., 1996 Turkey | 2 | Subconjunctival | Lidocaine | | <4 cc | Yes | Can't tell | | None planned
Kapran, Uyar, Eltutar et al., 1996 Turkey | 2 | Subconjunctival | Bupivacaine | | <4 cc | Yes | Can't tell | | None planned
Kershner, 1993 USA | 1 | Topical | Proparacaine | | | No | PE | | None planned
Khoo, Lim, and Yong, 1996 Singapore | 1 | Subconjunctival | Lidocaine | Hyaluronidase Epinephrine | <4 cc | Yes | Can't tell | | None planned
Khoo, Lim, and Yong, 1996 Singapore | 2 | Retrobulbar 50 mm 26 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Khurana, Sachdeva, Gombar et al., 1994 India | 1 | Peribulbar 25 mm 23 Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Khurana, Sachdeva, Gombar et al., 1994 India | 1 | Peribulbar 25 mm 23 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Superomedial | No | Can't tell | | None planned
Khurana, Sachdeva, Gombar et al., 1994 India | 1 | Peribulbar 25 mm 23 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | | None planned
Khurana, Sachdeva, Gombar et al., 1994 India | 1 | Peribulbar 25 mm 23 Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Superomedial | No | Can't tell | | None planned
Khurana, Sachdeva, Gombar et al., 1994 India | 2 | Subconjunctival | Lidocaine | Hyaluronidase Epinephrine | <4 cc | No | Can't tell | | None planned
Khurana, Sachdeva, Gombar et al., 1994 India | 2 | Subconjunctival | Bupivacaine | Hyaluronidase Epinephrine | <4 cc | No | Can't tell | | None planned
Kishore, Agarwal, Sood et al., 1990 India | 1 | Peribulbar 0.5 inches 26 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | 18 | None planned
Kishore, Agarwal, Sood et al., 1990 India | 1 | Peribulbar 0.5 inches 26 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | No | Can't tell | 18 | None planned
Kishore, Agarwal, Sood et al., 1990 India | 1 | Peribulbar 0.5 inches 26 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | 18 | None planned
Kishore, Agarwal, Sood et al., 1990 India | 1 | Peribulbar 0.5 inches 26 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | No | Can't tell | 18 | None planned
Koch, 1997 USA | 1 | Topical | Proparacaine | | 3 | No | PE clear cornea | | None planned
Kollarits, Jaweed, and Kollarits, 1998 USA | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | 4-6 cc Can't tell | No | PE | | None planned
Kollarits, Jaweed, and Kollarits, 1998 USA | 2 | Subconjunctival | Lidocaine | | <4 cc | No | PE | | None planned
Kothari, Shah, Shah et al., 1998 India | 1 | Peribulbar 0.625 inches 25 Not specified Topical | Lidocaine Lidocaine | Hyaluronidase | 4-6 cc Inferotemporal 6 | No | PE | | IV benzodiazepines
Krause, Weindler, and Ruprecht, 1997 Germany | 1 | Retrobulbar 35 mm 25 Blunt | Lidocaine | Hyaluronidase Anesthesia warming | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Krause, Weindler, and Ruprecht, 1997 Germany | 1 | Retrobulbar 35 mm 25 Blunt | Bupivacaine | Hyaluronidase Anesthesia warming | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Krause, Weindler, and Ruprecht, 1997 Germany | 2 | Retrobulbar 35 mm 25 Blunt | Lidocaine | Hyaluronidase Anesthesia warming | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Krause, Weindler, and Ruprecht, 1997 Germany | 2 | Retrobulbar 35 mm 25 Blunt | Bupivacaine | Hyaluronidase Anesthesia warming | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Krohn, Seland, Hovding et al., 1993 Norway | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Transconjunctival | Yes | ECCE | | Oral
Krohn, Seland, Hovding et al., 1993 Norway | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Epinephrine | 4-6 cc Transconjunctival | Yes | ECCE | | Oral
Kumar, Bose, Bhattacharya et al., 1992 India | 1 | Retrobulbar No details | | | | Yes | ICCE | 45 | Oral
Kumar, Bose, Bhattacharya et al., 1992 India | 2 | Retrobulbar No details | | | | Yes | ICCE | 50 | Oral
Lewis, Hamilton, Brant et al., 1992 Canada | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | >6 cc Inferomedial | No | Can't tell | | None planned
Lewis, Hamilton, Brant et al., 1992 Canada | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | >6 cc Inferotemporal | No | Can't tell | | None planned
Lewis, Hamilton, Brant et al., 1992 Canada | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase pH buffering | >6 cc Inferotemporal | No | Can't tell | | None planned
Lewis, Hamilton, Brant et al., 1992 Canada | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase pH buffering | >6 cc Inferomedial | No | Can't tell | | None planned
Loots, Koorts, and Venter, 1993 South Africa | 1 | Peribulbar 40 mm 25 Not specified | Bupivacaine | Hyaluronidase | >6 cc Can't tell | No | Can't tell | | None planned
Loots, Koorts, and Venter, 1993 South Africa | 2 | Peribulbar 40 mm 25 Not specified | Bupivacaine | Hyaluronidase | >6 cc Can't tell | No | Can't tell | | None planned
Loots, Koorts, and Venter, 1993 South Africa | 3 | Peribulbar 40 mm 25 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | None planned
Loots, Koorts, and Venter, 1993 South Africa | 3 | Peribulbar 40 mm 25 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | None planned
Maclean, Burton, and Murray, 1997 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Transconjunctival | No | PE | 13 | None planned
Maclean, Burton, and Murray, 1997 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Inferotemporal | No | PE | 13 | None planned
Maclean, Burton, and Murray, 1997 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Transconjunctival | No | PE | 13 | None planned
Maclean, Burton, and Murray, 1997 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | No | PE | 13 | None planned
Maclean, Burton, and Murray, 1997 UK | 2 | Subconjunctival Topical | Lidocaine Bupivacaine | | <4 cc | No | PE | 14 | None planned
Manners and Burton, 1996 UK | 1 | Subconjunctival Blunt Topical | Lidocaine Amethocaine | | <4 cc | | PE | | None planned
Manners and Burton, 1996 UK | 2 | Subconjunctival | Prilocaine | | <4 cc | No | PE | | None planned
Masket and Gokmen, 1998 USA | 1 | Topical | Tetracaine Lidocaine | | | No | PE clear cornea | | IV benzodiazepines IV analgesics
Masket and Gokmen, 1998 USA | 2 | Topical | Tetracaine Lidocaine Intracameral lidocaine | | | No | PE clear cornea | | IV benzodiazepines IV analgesics
Mindel, 1978 USA | 1 | Retrobulbar Can't tell 25 Not specified | Mepivicaine | Hyaluronidase | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Mindel, 1978 USA | 2 | Retrobulbar Can't tell 25 Not specified | Mepivicaine | | <4 cc Inferotemporal | Yes | Can't tell | | None planned
Morsman and Holden, 1992 Finland | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | ECCE | | None planned
Morsman and Holden, 1992 Finland | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | ECCE | | None planned
Morsman and Holden, 1992 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | 4-6 cc Inferotemporal | No | ECCE | | None planned
Morsman and Holden, 1992 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Inferotemporal | No | ECCE | | None planned
Morsman and Holden, 1992 Finland | 3 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Epinephrine | 4-6 cc Inferotemporal | No | ECCE | | None planned
Morsman and Holden, 1992 Finland | 3 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Epinephrine | 4-6 cc Inferotemporal | No | ECCE | | None planned
Morsman and Holden, 1992 Finland | 4 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | 4-6 cc Inferotemporal | No | ECCE | | None planned
Morsman and Holden, 1992 Finland | 4 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | 4-6 cc Inferotemporal | No | ECCE | | None planned
Muller, Claasen, Schall et al., 1996 South Africa | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | >6 cc Superomedial | No | ECCE | | None planned
Muller, Claasen, Schall et al., 1996 South Africa | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | >6 cc Inferotemporal | No | ECCE | | None planned
Muller, Claasen, Schall et al., 1996 South Africa | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | >6 cc Superomedial | No | ECCE | | None planned
Muller, Claasen, Schall et al., 1996 South Africa | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | >6 cc Inferotemporal | No | ECCE | | None planned
Murdoch, 1990 UK | 1 | Retrobulbar Can't tell Can't tell Not specified Topical | Bupivacaine | | <4 cc Inferotemporal | | ECCE | | None planned
Murdoch, 1990 UK | 1 | Retrobulbar Can't tell Can't tell Not specified Topical | Lidocaine | | <4 cc Inferotemporal | | ECCE | | None planned
Murdoch, 1990 UK | 1 | Subconjunctival Topical | Lidocaine | | Can't tell | | ECCE | | None planned
Murdoch, 1990 UK | 1 | Subconjunctival Topical | Bupivacaine | | Can't tell | | ECCE | | None planned
Murdoch, 1990 UK | 2 | Peribulbar Can't tell 27 (0.4 mm) Not specified Topical | Bupivacaine | Hyaluronidase | <4 cc Superomedial | Yes | ECCE | | None planned
Murdoch, 1990 UK | 2 | Peribulbar Can't tell 27 (0.4 mm) Not specified Topical | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | Yes | ECCE | | None planned
Murdoch, 1990 UK | 2 | Peribulbar Can't tell 27 (0.4 mm) Not specified Topical | Lidocaine | Hyaluronidase | <4 cc Superomedial | Yes | ECCE | | None planned
Murdoch, 1990 UK | 2 | Peribulbar Can't tell 27 (0.4 mm) Not specified Topical | Lidocaine | Hyaluronidase | <4 cc Inferotemporal | Yes | ECCE | | None planned
Nathan, Benrhaiem, Lotfi et al., 1996 France | 1 | Peribulbar Can't tell 23 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | No details
Nathan, Benrhaiem, Lotfi et al., 1996 France | 1 | Peribulbar Can't tell 23 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Inferomedial | No | Can't tell | | No details
Nathan, Benrhaiem, Lotfi et al., 1996 France | 1 | Peribulbar Can't tell 23 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Inferomedial | No | Can't tell | | No details
Nathan, Benrhaiem, Lotfi et al., 1996 France | 1 | Peribulbar Can't tell 23 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | No details
Nathan, Benrhaiem, Lotfi et al., 1996 France | 2 | Peribulbar Can't tell 23 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | No details
Nathan, Benrhaiem, Lotfi et al., 1996 France | 2 | Peribulbar Can't tell 23 Not specified | Lidocaine | Hyaluronidase | 4-6 cc Inferomedial | No | Can't tell | | No details
Nathan, Benrhaiem, Lotfi et al., 1996 France | 2 | Peribulbar Can't tell 23 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Inferomedial | No | Can't tell | | No details
Nathan, Benrhaiem, Lotfi et al., 1996 France | 2 | Peribulbar Can't tell 23 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | No details
Nielsen, 1995 Denmark | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | PE clear cornea | | None planned
Nielsen, 1995 Denmark | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | PE clear cornea | | None planned
Nielsen, 1995 Denmark | 2 | Topical | Lidocaine | | 9 | No | PE clear cornea | | None planned
Nielsen and Allerod, 1998 Denmark | 1 | Retrobulbar Can't tell 27 Sharp | Bupivacaine | Hyaluronidase | Can't tell Can't tell | No | PE clear cornea | 15 | None planned
Nielsen and Allerod, 1998 Denmark | 1 | Retrobulbar Can't tell 27 Sharp | Lidocaine | Hyaluronidase | Can't tell Can't tell | No | PE clear cornea | 15 | None planned
Nielsen and Allerod, 1998 Denmark | 2 | Subconjunctival | Bupivacaine | | <4 cc | No | PE clear cornea | 16 | None planned
Nielsen and Allerod, 1998 Denmark | 2 | Subconjunctival | Lidocaine | | <4 cc | No | PE clear cornea | 16 | None planned
Nielsen and Allerod, 1998 Denmark | 3 | Topical | Unpreserved lidocaine | | 9 | No | PE clear cornea | 16 | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Can't tell | Yes | Can't tell | | Oral
Nolan, Aziz, Ahmad et al., 1993 Ireland | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | Oral
Nolan, Aziz, Ahmad et al., 1993 Ireland | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 3 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 3 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 4 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | Yes | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 4 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | Yes | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 5 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | No | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 5 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | No | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 6 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 6 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 7 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | No | Can't tell | | None planned
Nolan, Aziz, Ahmad et al., 1993 Ireland | 7 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | No | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 1 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | 4-6 cc Inferotemporal | Yes | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 1 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | 4-6 cc Superomedial | Yes | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 2 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | 4-6 cc Inferotemporal | Yes | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 2 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | 4-6 cc Superomedial | Yes | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 3 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | >6 cc Superomedial | Yes | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 3 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | >6 cc Inferotemporal | Yes | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 4 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | >6 cc Inferotemporal | Yes | Can't tell | | None planned
Ortiz, Blanco, Serra et al., 1995 Spain | 4 | Peribulbar Can't tell 23 Blunt | Bupivacaine | Chondroitin sultatase | >6 cc Superomedial | Yes | Can't tell | | None planned
Pappa, Pouliou, Nastou et al., 1995 Greece | 1 | Retrobulbar No details Topical | No details EMLA | | | Can't tell | Can't tell | | IV analgesic
Pappa, Pouliou, Nastou et al., 1995 Greece | 2 | Retrobulbar No details | No details | | | Can't tell | Can't tell | | IV analgesic
Patel, Burns, Crandall et al., 1996 USA | 1 | Topical | Bupivacaine | | 8 | | PE clear cornea | | IV benzodiazepines IV analgesics
Patel, Burns, Crandall et al., 1996 USA | 2 | Retrobulbar Can't tell 23 Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | | PE clear cornea | | IV barbiturates
Patel, Burns, Crandall et al., 1996 USA | 2 | Retrobulbar Can't tell 23 Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | | PE clear cornea | | IV barbiturates
Patel, Clinch, Burns et al., 1998 USA | 1 | Topical | Bupivacaine | | 8 | No | PE clear cornea | 24 | IV benzodiazepines IV analgesics
Patel, Clinch, Burns et al., 1998 USA | 2 | Retrobulbar Can't tell 25 Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | PE clear cornea | 21 | IV barbiturates
Patel, Clinch, Burns et al., 1998 USA | 2 | Retrobulbar Can't tell 25 Not specified Topical | Lidocaine Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | PE clear cornea | 21 | IV barbiturates
Pecka and Dexter, 1997 USA | 1 | Retrobulbar No details | | | | | Can't tell | | No details
Petersen and Yanoff, 1991 USA | 1 | Subconjunctival | Lidocaine | Hyaluronidase Epinephrine | <4 cc | No | PE | | IV benzodiazepines
Prosser, Rodney, Mian et al., 1996 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | Can't tell Can't tell | | Can't tell | | None planned
Prosser, Rodney, Mian et al., 1996 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | | Can't tell | | None planned
Prosser, Rodney, Mian et al., 1996 UK | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | Can't tell Can't tell | | Can't tell | | None planned
Prosser, Rodney, Mian et al., 1996 UK | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | Can't tell Can't tell | | Can't tell | | None planned
Redmond and Dallas, 1990 UK | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | ECCE | Can't tell | None
Redmond and Dallas, 1990 UK | 1 | Subconjunctival/sub-Tenon's 23 gauge | Bupivacaine | Hyaluronidase | <4 cc | Yes | ECCE | Can't tell | None
Roman, Auclin, and Ullern, 1996 France | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | 4-6 cc Inferotemporal | No | PE clear cornea | | IV analgesics IV propofol
Roman, Auclin, and Ullern, 1996 France | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | | 4-6 cc Superotemporal | No | PE clear cornea | | IV analgesics IV propofol
Roman, Auclin, and Ullern, 1996 France | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | 4-6 cc Inferotemporal | No | PE clear cornea | | IV analgesics IV propofol
Roman, Auclin, and Ullern, 1996 France | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | | 4-6 cc Superotemporal | No | PE clear cornea | | IV analgesics IV propofol
Roman, Auclin, and Ullern, 1996 France | 2 | Topical | Tetracaine | | 12 | No | PE clear cornea | | IV propofol
Roper and Nisbet, 1978 USA | 1 | Retrobulbar No details | | | | No | Can't tell | | None planned
Roper and Nisbet, 1978 USA | 2 | Retrobulbar No details | | Hyaluronidase | | No | Can't tell | | None planned
Ropo, Ruusuvaara, Paloheimo et al., 1990 Finland | 1 | Peribulbar 25mm 25 Sharp | Etidocaine | Hyaluronidase Ocular compression | >6 cc Superomedial Inferomedial Superotemporal Inferotemporal | Yes | Can't tell | Not stated | Can't tell
Ropo, Ruusuvaara, Paloheimo et al., 1990 Finland | 2 | Peribulbar 25mm 25 Sharp | Etidocaine | Hyaluronidase Ocular compression | >6 cc Superomedial Inferomedial Superotemporal Inferotemporal | Yes | Can't tell | Not stated | Can't tell
Ropo, Ruusuvaara, Paloheimo et al., 1990 Finland | 3 | Peribulbar 25mm 25 Sharp | Etidocaine | Hyaluronidase Ocular compression | >6 cc Superomedial Inferomedial Superotemporal Inferotemporal | Yes | Can't tell | Not stated | Can't tell
Ruusuvaara, Setala, Pajari et al., 1995 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | | <4 cc Can't tell | Yes | Can't tell | | None planned
Ruusuvaara, Setala, Pajari et al., 1995 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | Yes | Can't tell | | None planned
Ruusuvaara, Setala, Pajari et al., 1995 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | Yes | Can't tell | | None planned
Sanchez-Capuchino, Meadows, and Morgan, 1993 UK | 1 | Retrobulbar Can't tell Can't tell Not specified | Prilocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | Oral
Sanchez-Capuchino, Meadows, and Morgan, 1993 UK | 2 | Retrobulbar Can't tell Can't tell Not specified | Prilocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | Oral
Sanders, Ahmed, Craig et al., 1997 UK | 1 | Peribulbar 25 mm Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | >6 cc Superomedial | No | ECCE | | None planned
Sanders, Ahmed, Craig et al., 1997 UK | 1 | Peribulbar 25 mm Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | >6 cc Inferotemporal | No | ECCE | | None planned
Sanders, Ahmed, Craig et al., 1997 UK | 2 | Retrobulbar 40 mm Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Can't tell | Yes | ECCE | | None planned
Sarvela and Nikki, 1992b Finland | 1 | Peribulbar 22 mm 25 Blunt | Etidocaine | Hyaluronidase | >4 cc Inferotemporal | No | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992b Finland | 2 | Peribulbar 31 mm 23 Blunt | Etidocaine | Hyaluronidase | >6 cc Inferomedial | No | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992b Finland | 2 | Peribulbar 31 mm 23 Blunt | Etidocaine | Hyaluronidase | >6 cc Inferotemporal | No | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 1 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Inferotemporal | Yes | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 2 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Inferotemporal | Yes | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 3 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Inferotemporal | | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 3 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Transconjunctival | | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 3 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Inferomedial | | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 4 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Inferotemporal | | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 4 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Transconjunctival | | Can't tell | | Oral IV analgesics
Sarvela and Nikki, 1992a Finland | 4 | Peribulbar 25 mm 25 Sharp | Etidocaine | Hyaluronidase | 4-6 cc Inferomedial | | Can't tell | | Oral IV analgesics
Sarvela, 1993 Finland | 1 | Peribulbar 12 mm 30 (0.3 mm) Not specified | Etidocaine | Hyaluronidase | <4 cc Transconjunctival | No | Can't tell | 43 | Oral IV analgesics
Sarvela, 1993 Finland | 1 | Retrobulbar 31.25 mm 27 (0.4 mm) Sharp | Etidocaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | 43 | Oral IV analgesics
Sarvela, 1993 Finland | 1 | Topical | Oxybuprocaine | | Not specified | No | Can't tell | 43 | Oral IV analgesics
Sarvela, 1993 Finland | 2 | Peribulbar 12 mm 30 (0.3 mm) Not specified | Etidocaine | Hyaluronidase | <4 cc Transconjunctival | No | Can't tell | 36 | Oral IV analgesics
Sarvela, 1993 Finland | 2 | Retrobulbar 31.25 mm 27 (0.4 mm) Sharp | Etidocaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | 36 | Oral IV analgesics
Sarvela, 1993 Finland | 2 | Topical | Oxybuprocaine | | | No | Can't tell | 36 | Oral IV analgesics
Sarvela, 1993 Finland | 3 | Peribulbar 12 mm 30 (0.3 mm) Not specified Topical | Bupivacaine | Hyaluronidase | <4 cc Transconjunctival | No | Can't tell | 37 | Oral IV analgesics
Sarvela, 1993 Finland | 3 | Retrobulbar 31.25 mm 27 (0.4 mm) Sharp Topical | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | 37 | Oral IV analgesics
Sarvela, 1993 Finland | 3 | Topical | Oxybuprocaine | | | No | Can't tell | 37 | Oral IV analgesics
Sarvela, 1993 Finland | 4 | Peribulbar 12 mm 30 (0.3 mm) Not specified | Bupivacaine | Hyaluronidase | <4 cc Transconjunctival | No | Can't tell | 39 | Oral IV analgesics
Sarvela, 1993 Finland | 4 | Retrobulbar 31.25 mm 27 (0.4 mm) Sharp | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | 39 | Oral IV analgesics
Sarvela, 1993 Finland | 4 | Topical | Oxybuprocaine | | | No | Can't tell | 39 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 1 | Peribulbar 12 mm 30 (0.3 mm) Not specified | Bupivacaine | Hyaluronidase | <4 cc Transconjunctival | No | Can't tell | 36 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 1 | Retrobulbar 31 mm 27 (0.4 mm) Sharp | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | 36 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 2 | Peribulbar 12 mm 30 (0.3 mm) Not specified | Bupivacaine | Hyaluronidase | <4 cc Transconjunctival | No | Can't tell | 37 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 2 | Retrobulbar 31 mm 27 (0.4 mm) Sharp | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | No | Can't tell | 37 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 3 | Peribulbar 12 mm 30 (0.3 mm) Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Transconjunctival | No | Can't tell | 36 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 3 | Retrobulbar 31 mm 27 (0.4 mm) Sharp | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | 36 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 4 | Retrobulbar 31 mm 27 (0.4 mm) Sharp | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | 40 | Oral IV analgesics
Sarvela, Nikki, and Paloheimo, 1993 Finland | 4 | Peribulbar 12 mm 30 (0.3 mm) Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Transconjunctival | No | Can't tell | 40 | Oral IV analgesics
Sarvela, Paloheimo, and Nikki, 1994 Finland | 1 | Peribulbar Can't tell Can't tell Sharp | Bupivacaine | Hyaluronidase | >6 cc Inferotemporal | Yes | PE | | None planned
Sarvela, Paloheimo, and Nikki, 1994 Finland | 1 | Peribulbar Can't tell Can't tell Sharp | Bupivacaine | Hyaluronidase | >6 cc Transconjunctival | Yes | PE | | None planned
Sarvela, Paloheimo, and Nikki, 1994 Finland | 1 | Peribulbar Can't tell Can't tell Sharp | Lidocaine | Hyaluronidase | >6 cc Transconjunctival | Yes | PE | | None planned
Sarvela, Paloheimo, and Nikki, 1994 Finland | 1 | Peribulbar Can't tell Can't tell Sharp | Lidocaine | Hyaluronidase | >6 cc Inferotemporal | Yes | PE | | None planned
Sarvela, Paloheimo, and Nikki, 1994 Finland | 2 | Peribulbar Can't tell Can't tell | Lidocaine | Hyaluronidase | <4 cc Inferotemporal | Yes | PE | | None planned
Sarvela, Paloheimo, and Nikki, 1994 Finland | 2 | Peribulbar Can't tell Can't tell | Lidocaine | Hyaluronidase | <4 cc Transconjunctival | Yes | PE | | None planned
Sarvela, Paloheimo, and Nikki, 1994 Finland | 2 | Peribulbar Can't tell Can't tell | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | Yes | PE | | None planned
Sarvela, Paloheimo, and Nikki, 1994 Finland | 2 | Peribulbar Can't tell Can't tell | Bupivacaine | Hyaluronidase | <4 cc Transconjunctival | Yes | PE | | None planned
Saunders, Sturgess, Pemberton et al., 1993 UK | 1 | Retrobulbar 40 mm 25 Not specified | Pilocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | Oral
Saunders, Sturgess, Pemberton et al., 1993 UK | 2 | Peribulbar 16 mm 25 Not specified | Prilocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | No | Can't tell | | Oral
Saunders, Sturgess, Pemberton et al., 1993 UK | 2 | Peribulbar 16 mm 25 Not specified | Prilocaine | Hyaluronidase Epinephrine | <4 cc Superomedial | No | Can't tell | | Oral
Schimek, Steuhl, and Fahle, 1993 Germany | 1 | Retrobulbar 38 mm 21g Not specified | Lidocaine | Hyaluronidase Naphazoline | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Schimek, Steuhl, and Fahle, 1993 Germany | 2 | Retrobulbar 38 mm 21g Not specified | Prilocaine | Hyaluronidase Naphazoline | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Schimek, Steuhl, and Fahle, 1993 Germany | 3 | Retrobulbar 38 mm 21g Not specified | Mepivicaine | Hyaluronidase Naphazoline | <4 cc Inferotemporal | | Can't tell | | Oral
Scott, Jakeman, Perry et al., 1995 UK | 1 | Peribulbar 16 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Scott, Jakeman, Perry et al., 1995 UK | 1 | Peribulbar 16 mm 25 Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Scott, Jakeman, Perry et al., 1995 UK | 2 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | Yes | Can't tell | | None planned
Scott, Jakeman, Perry et al., 1995 UK | 2 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Inferotemporal | Yes | Can't tell | | None planned
Shammas, Milkie, and Yeo, 1997 USA | 1 | Subconjunctival Can't tell | Lidocaine | | <4 cc | No | PE | 23 | IV barbiturates
Shammas, Milkie, and Yeo, 1997 USA | 1 | Retrobulbar 35 mm 27 (0.4 mm) Not specified | Lidocaine | | <4 cc Inferotemporal | No | PE | 23 | IV barbiturates
Shammas, Milkie, and Yeo, 1997 USA | 2 | Subconjunctival | Lidocaine | | <4 cc | No | PE | 22 | IV benzodiazepines IV analgesics
Shammas, Milkie, and Yeo, 1997 USA | 2 | Topical | Lidocaine | | | No | PE | 22 | IV benzodiazepines IV analgesics
Shibata, Inage, Takayama et al., 1993 Japan | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Cold spray, 1st eye sprayed | >6 cc Can't tell | Yes | Can't tell | | None planned
Shibata, Inage, Takayama et al., 1993 Japan | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Cold spray, 2nd eye sprayed | >6 cc Can't tell | Yes | Can't tell | | None planned
Smith and Kim, 1980 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Can't tell | Yes | Can't tell | | Oral
Smith and Kim, 1980 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | Hyaluronidase Epinephrine | <4 cc Can't tell | Yes | Can't tell | Oral
Smith and Smith, 1983 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Can't tell | Yes | Can't tell | | No details
Smith and Smith, 1983 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | No details
Smith and Smith, 1983 USA | 3 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | Epinephrine | <4 cc Can't tell | Yes | Can't tell | | No details
Smith, Kemp, and Smith, 1987 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | No details
Smith, Kemp, and Smith, 1987 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | No details
Smith, Kemp, and Smith, 1987 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | No details
Sunderraj, Kirby, Joyce et al., 1991 UK | 1 | Retrobulbar 30 mm 23 Not specified Topical | Bupivacaine EMLA | Hyaluronidase | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Sunderraj, Kirby, Joyce et al., 1991 UK | 2 | Retrobulbar 30 mm 23 Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Suzuki, Kuroki, and Fujiwara, 1997 Japan | 1 | Topical | Lidocaine | | | No | PE | 7 | Oral
Suzuki, Kuroki, and Fujiwara, 1997 Japan | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | No | PE | 9 | Oral
Sweeney, Barber, and Prosser, 1993 Australia | 1 | Peribulbar 30 mm 23 Not specified | Lidocaine | Hyaluronidase Epinephrine | Can't tell Inferomedial | Yes | Can't tell | | None planned
Sweeney, Barber, and Prosser, 1993 Australia | 1 | Peribulbar 30 mm 23 Not specified | Lidocaine | Hyaluronidase Epinephrine | Can't tell Can't tell | Yes | Can't tell | | None planned
Sweeney, Barber, and Prosser, 1993 Australia | 2 | Peribulbar 25 mm Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | Can't tell Inferomedial | No | Can't tell | | None planned
Sweeney, Barber, and Prosser, 1993 Australia | 2 | Peribulbar 25 mm Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | Can't tell Transconjunctival | No | Can't tell | | None planned
Thomson, 1988 Ghana | 1 | Retrobulbar 50 mm 26 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferomedial | Yes | ICCE | | Oral
Thomson, 1988 Ghana | 1 | Retrobulbar 50 mm 26 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | Yes | ICCE | Oral
Thomson, 1988 Ghana | 2 | Retrobulbar 50 mm 26 Not specified | Lidocaine | Epinephrine | <4 cc Inferotemporal | Yes | ICCE | | Oral
Thomson, 1988 Ghana | 2 | Retrobulbar 50 mm 26 Not specified | Lidocaine | Epinephrine | <4 cc Inferomedial | Yes | ICCE | | Oral
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | 1 | Peribulbar Can't tell Can't tell Not specified | Mepivicaine | | <4 cc Superomedial | Yes | Can't tell | | Oral
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | 1 | Retrobulbar Can't tell Can't tell Not specified | Mepivicaine | | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | 2 | Peribulbar Can't tell Can't tell Not specified | Etidocaine | | <4 cc Superomedial | Yes | Can't tell | | Oral
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | 2 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | 3 | Peribulbar Can't tell Can't tell Not specified | Etidocaine | | <4 cc Superomedial | Yes | Can't tell | | Oral
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | 3 | Retrobulbar Can't tell Can't tell Not specified | Etidocaine | | <4 cc Inferotemporal | Yes | Can't tell | | Oral
Tseng and Chen, 1998 Taiwan | 1 | Topical | Lidocaine Placebo Intracameral Saline | | 10 | | PE clear cornea | | Oral
Tseng and Chen, 1998 Taiwan | 2 | Topical | Lidocaine Intracameral Lidocaine | | 10 | | PE clear cornea | | Oral
Ursell and Spalton, 1996 UK | 1 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase Anesthesia warming | <4 cc Inferotemporal | No | PE | | None planned
Ursell and Spalton, 1996 UK | 1 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase Anesthesia warming | <4 cc Inferotemporal | No | PE | | None planned
Ursell and Spalton, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Lidocaine | Hyaluronidase | <4 cc Inferotemporal | No | PE | | None planned
Ursell and Spalton, 1996 UK | 2 | Peribulbar 25 mm 25 Not specified | Bupivacaine | Hyaluronidase | <4 cc Inferotemporal | No | PE | | None planned
Uusitalo, Maunuksela, Paloheimo et al., 1999 Finland | 1 | Topical | Bupivacaine | | 10 | No | PE clear cornea | 19 | IV analgesics
Uusitalo, Maunuksela, Paloheimo et al., 1999 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | PE clear cornea | 17 | IV analgesics
Uusitalo, Maunuksela, Paloheimo et al., 1999 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | PE clear cornea | 17 | IV analgesics
Vettese and Breslin, 1985 Canada | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | IV benzodiazepines
Vettese and Breslin, 1985 Canada | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | IV benzodiazepines
Vettese and Breslin, 1985 Canada | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | IV benzodiazepines
Vettese and Breslin, 1985 Canada | 3 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Can't tell | Yes | Can't tell | | IV benzodiazepines
Vettese and Breslin, 1985 Canada | 3 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Can't tell | Yes | Can't tell | | IV benzodiazepines
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | 1 | Peribulbar 1.25 inches 23g Sharp | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 37 | IV analgesics
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | 1 | Peribulbar 1.25 inches 23g Sharp | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 37 | IV analgesics
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | 2 | Peribulbar 1.25 inches 23g Sharp | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 38 | IV benzodiazepines
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | 2 | Peribulbar 1.25 inches 23g Sharp | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 38 | IV benzodiazepines
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | 3 | Peribulbar 1.25 inches 23g Sharp | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 36 | Placebo
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | 3 | Peribulbar 1.25 inches 23g Sharp | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 36 | Placebo
Virtanen and Huha, 1998 Finland | 1 | Peribulbar Can't tell 25 Not specified Topical | Bupivacaine | Hyaluronidase | Can't tell Inferotemporal | No | PE | | None planned
Virtanen and Huha, 1998 Finland | 1 | Peribulbar Can't tell 25 Not specified | Lidocaine | Hyaluronidase | Can't tell Inferotemporal | No | PE | | None planned
Virtanen and Huha, 1998 Finland | 2 | Topical | Oxybuprocaine | | | No | PE | | None planned
Waller, Taboada, and O'Connor, 1993 USA | 1 | Retrobulbar No details | | | | | Can't tell | | None planned
Weiss and Deichman, 1989 USA | 1 | Retrobulbar 37.5 mm 25 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | | Can't tell | | None planned
Weiss and Deichman, 1989 USA | 1 | Retrobulbar 37.5 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | | Can't tell | | None planned
Weiss and Deichman, 1989 USA | 2 | Peribulbar 16 mm 25 Not specified | Bupivacaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | | Can't tell | | None planned
Weiss and Deichman, 1989 USA | 2 | Peribulbar 16 mm 25 Not specified | Lidocaine | Hyaluronidase Epinephrine | <4 cc Inferotemporal | | Can't tell | | None planned
Whitsett, Balyeat, and McClure, 1990 USA | 1 | Peribulbar 7/8 inches 26 Sharp | Lidocaine | Hyaluronidase Slow injection | <4 cc Inferotemporal | No | ECCE | | None planned
Whitsett, Balyeat, and McClure, 1990 USA | 1 | Peribulbar 7/8 inches 26 Sharp | Bupivacaine | Hyaluronidase Slow injection | <4 cc Inferotemporal | No | ECCE | | None planned
Whitsett, Balyeat, and McClure, 1990 USA | 2 | Retrobulbar 1.5 26g | Bupivacaine | Hyaluronidase Slow injection | <4 cc Can't tell | Yes | ECCE | | None planned
Whitsett, Balyeat, and McClure, 1990 USA | 2 | Retrobulbar 1.5 26g | Lidocaine | Hyaluronidase Slow injection | <4 cc Can't tell | Yes | ECCE | | None planned
Wolf, Lynch, and Berlin, 1975 USA | 1 | Retrobulbar No details | | | | | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 1 | Retrobulbar 35 mm 27 (0.4 mm) Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 1 | Retrobulbar 35 mm 27 (0.4 mm) Not specified | Lidocaine | Hyaluronidase | 4-6 cc Inferotemporal | No | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 2 | Peribulbar 35 mm 27 (0.4 mm) Not specified | Lidocaine | Hyaluronidase | >6 cc Inferotemporal | No | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 2 | Peribulbar 35 mm 27 (0.4 mm) Not specified | Lidocaine | Hyaluronidase | >6 cc Superomedial | No | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 2 | Peribulbar 35 mm 27 (0.4 mm) Not specified | Bupivacaine | Hyaluronidase | >6 cc Superomedial | No | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 2 | Peribulbar 35 mm 27 (0.4 mm) Not specified | Bupivacaine | Hyaluronidase | >6 cc Inferotemporal | No | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 3 | Retrobulbar 35 mm 27 (0.4 mm) Not specified | Lidocaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | None planned
Wong, Koehrer, Sutton et al., 1993 Canada | 3 | Retrobulbar 35 mm 27 (0.4 mm) Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Superomedial | No | Can't tell | | None planned
Zehetmayer, Radax, Skorpik et al., 1996 Austria | 1 | Topical | Lidocaine | | 9 | Yes | PE clear cornea | | Oral
Zehetmayer, Radax, Skorpik et al., 1996 Austria | 2 | Peribulbar 0.75 inches 26 Sharp | Bupivacaine | Hyaluronidase pH buffering | <4 cc Inferotemporal | Yes | PE clear cornea | | Oral
Zehetmayer, Radax, Skorpik et al., 1996 Austria | 2 | Peribulbar 0.75 inches 26 Sharp | Lidocaine | Hyaluronidase pH buffering | <4 cc Inferotemporal | Yes | PE clear cornea | | Oral
Zehetmayer, Rainer, Turnheim et al., 1997 Austria | 1 | Topical | Lidocaine Oxybuprocaine | | 9 | No | PE clear cornea | 16 | Oral
Zehetmayer, Rainer, Turnheim et al., 1997 Austria | 2 | Topical | Lidocaine Oxybuprocaine | | 9 | No | PE clear cornea | 16 | Oral
Main Topic: Regional Anesthesia and Sedation
Boezaart, Berry, Laubscher et al., 1998 South Africa | 1 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 1 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 1 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 1 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 1 | Retrobulbar 35 21 Sharp | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 1 | Retrobulbar 25 21 Sharp | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 2 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 2 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 2 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 2 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 2 | Retrobulbar 35 21 Sharp | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 2 | Retrobulbar 25 21 Sharp | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 3 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 3 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 3 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 3 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 3 | Retrobulbar 35 mm. 21 Sharp | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 3 | Retrobulbar 35 mm. 21 Sharp | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 4 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 4 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 4 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 4 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 4 | Retrobulbar 35 mm. 21 Sharp | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 4 | Retrobulbar 35 mm. 21 Sharp | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 5 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 5 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 5 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 5 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 5 | Retrobulbar 35 mm. 21 Sharp | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 5 | Retrobulbar 35 mm. 21 Sharp | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 6 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 6 | Peribulbar 12.5 mm 29 Not specified | Lidocaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 6 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Superomedial | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 6 | Peribulbar 12.5 mm 29 Not specified | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 6 | Retrobulbar 35 mm. 21 Sharp | Bupivacaine | | <4 cc Inferotemporal | No | PE | | Oral
Boezaart, Berry, Laubscher et al., 1998 South Africa | 6 | Retrobulbar 35 mm. 21 Sharp | Lidocaine | | <4 cc Inferotemporal | No | PE | | Oral
Cruise, Chung, Yogendran et al., 1997 Canada | 1 | Retrobulbar No details | | | | No | Can't tell | | IV benzodiazepines IV analgesics
Cruise, Chung, Yogendran et al., 1997 Canada | 2 | Retrobulbar No details | | | | No | Can't tell | | IV benzodiazepines IV analgesics
Cruise, Chung, Yogendran et al., 1997 Canada | 3 | Retrobulbar No details | | | | No | Can't tell | | IV benzodiazepines IV analgesics
Cruise, Chung, Yogendran et al., 1997 Canada | 4 | Retrobulbar No details | | | | No | Can't tell | | IV benzodiazepines IV analgesics
el-Bassiouny, el-Taher, and el-Din, 1992 Egypt | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | >6 cc Can't tell | Yes | Can't tell | 36 | Oral IV analgesics IV other
el-Bassiouny, el-Taher, and el-Din, 1992 Egypt | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | 4-6 cc Can't tell | Yes | Can't tell | 36 | Oral IV analgesics IV other
el-Bassiouny, el-Taher, and el-Din, 1992 Egypt | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | >6 cc Can't tell | Yes | Can't tell | 38 | Oral IV other
el-Bassiouny, el-Taher, and el-Din, 1992 Egypt | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | 4-6 cc Can't tell | Yes | Can't tell | 38 | Oral IV other
Mjahed, el Harrar, Hamdani et al., 1996 Morocco | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | Yes | Can't tell | | None planned
Mjahed, el Harrar, Hamdani et al., 1996 Morocco | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Clonidine | <4 cc Can't tell | Yes | Can't tell | | None planned
Wong and Merrick, 1996 Canada | 1 | Peribulbar 27 (0.4 mm) | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV other
Wong and Merrick, 1996 Canada | 1 | Peribulbar 27 (0.4 mm) | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV other
Wong and Merrick, 1996 Canada | 2 | Peribulbar 27 (0.4 mm) | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV benzodiazepines
Wong and Merrick, 1996 Canada | 2 | Peribulbar 27 (0.4 mm) | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV benzodiazepines
Wong and Merrick, 1996 Canada | 3 | Peribulbar 27 (0.4 mm) | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV analgesics
Wong and Merrick, 1996 Canada | 3 | Peribulbar 27 (0.4 mm) | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV analgesics
Wong and Merrick, 1996 Canada | 4 | Peribulbar 27 (0.4 mm) | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV benzodiazepines IV analgesics
Wong and Merrick, 1996 Canada | 4 | Peribulbar 27 (0.4 mm) | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | | IV benzodiazepines IV analgesics
Main Topic: Sedation
Chung, Cheng, Seyone et al., 1990 Canada | 1 | Retrobulbar No details | | | | No | Can't tell | | IV benzodiazepines IV analgesics
Chung, Cheng, Seyone et al., 1990 Canada | 2 | Retrobulbar No details | | | | No | Can't tell | | IV benzodiazepines IV analgesics
Coley, Jones, Lassey et al., 1990 UK | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | Can't tell Can't tell | Yes | Can't tell | 28 | Oral IV analgesics IV other
Coley, Jones, Lassey et al., 1990 UK | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | Yes | Can't tell | 28 | Oral IV analgesics IV other
Coley, Jones, Lassey et al., 1990 UK | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | Can't tell Can't tell | Yes | Can't tell | 30 | Oral IV analgesics IV other
Coley, Jones, Lassey et al., 1990 UK | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | Yes | Can't tell | 30 | Oral IV analgesics IV other
Cugini, Lanzetta, Nadbath et al., 1997 Italy | 1 | Retrobulbar Can't tell Can't tell Not specified | Mepivicaine | | Can't tell Can't tell | Yes | Can't tell | | IV benzodiazepines IV other
Cugini, Lanzetta, Nadbath et al., 1997 Italy | 1 | Subconjunctival | Mepivicaine | | Can't tell | Yes | Can't tell | | IV benzodiazepines IV other
Cugini, Lanzetta, Nadbath et al., 1997 Italy | 2 | Retrobulbar Can't tell Can't tell Not specified | Mepivicaine | | Can't tell Can't tell | Yes | Can't tell | | IV benzodiazepines IV other
Cugini, Lanzetta, Nadbath et al., 1997 Italy | 2 | Subconjunctival | Mepivicaine | | Can't tell | Yes | Can't tell | | IV benzodiazepines IV other
Filos, Patroni, Goudas et al., 1993 Greece | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | Can't tell | ECCE | | Oral
Filos, Patroni, Goudas et al., 1993 Greece | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | Can't tell | ECCE | | Oral
Filos, Patroni, Goudas et al., 1993 Greece | 3 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | Can't tell | ECCE | | Oral
Gilbert, Holt, Johnston et al., 1987 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | 4-6 cc Can't tell | Yes | Can't tell | 84 | IV benzodiazepines IV analgesics
Gilbert, Holt, Johnston et al., 1987 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | 4-6 cc Can't tell | Yes | Can't tell | 84 | IV benzodiazepines IV analgesics
Gilbert, Holt, Johnston et al., 1987 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | 4-6 cc Can't tell | Yes | Can't tell | 76 | IV barbiturates
Gilbert, Holt, Johnston et al., 1987 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | 4-6 cc Can't tell | Yes | Can't tell | 76 | IV barbiturates
Herrick, Gelb, Nichols et al., 1996 Canada | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | 53 | IV propofol
Herrick, Gelb, Nichols et al., 1996 Canada | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | 53 | IV propofol
Herrick, Gelb, Nichols et al., 1996 Canada | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | 46 | IV propofol
Herrick, Gelb, Nichols et al., 1996 Canada | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | No | Can't tell | 46 | IV propofol
Ibrahim and Savino, 1974 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | IV benzodiazepines
Ibrahim and Savino, 1974 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | <4 cc Can't tell | Yes | Can't tell | | IV barbiturates IV analgesics IV other
Karhunen and Orko, 1981 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | No | Can't tell | 35 | IV other
Karhunen and Orko, 1981 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | Can't tell Can't tell | No | Can't tell | 32 | IV other
Khalil, Howard, Mankarious et al., 1998 USA | 1 | Retrobulbar 22g | Bupivacaine | Hyaluronidase | >6 cc Can't tell | No | Can't tell | | IV barbiturates IV analgesics
Khalil, Howard, Mankarious et al., 1998 USA | 2 | Retrobulbar 22g | Bupivacaine | Hyaluronidase | >6 cc Can't tell | No | Can't tell | | IV barbiturates
Khalil, Howard, Mankarious et al., 1998 USA | 3 | Retrobulbar 22g | Bupivacaine | Hyaluronidase | >6 cc Can't tell | No | Can't tell | | IV other
Kost and Emerson, 1992 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Kost and Emerson, 1992 USA | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Kost and Emerson, 1992 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV benzodiazepines IV analgesics
Kost and Emerson, 1992 USA | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV benzodiazepines IV analgesics
Kumar, Tandon, Bhattacharya et al., 1994 India | 1 | | | | | Yes | Can't tell | 50 | Oral
Kumar, Tandon, Bhattacharya et al., 1994 India | 2 | | | | | Yes | Can't tell | 55 | Oral
Michelson and Naujoks, 1991 Germany | 1 | Retrobulbar Can't tell Can't tell Not specified | Mepivicaine | Hyaluronidase Naphazoline | 4-6 cc Can't tell | Yes | Can't tell | | None planned
Michelson and Naujoks, 1991 Germany | 2 | Retrobulbar Can't tell Can't tell Not specified | Mepivicaine | Hyaluronidase Naphazoline | 4-6 cc Can't tell | Yes | Can't tell | | None planned
Oikkonen, 1994 Finland | 1 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | ECCE | 49 | Oral
Oikkonen, 1994 Finland | 1 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell Can't tell | No | ECCE | 49 | Oral
Oikkonen, 1994 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | ECCE | 49 | Oral
Oikkonen, 1994 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell Can't tell | No | ECCE | 49 | Oral
Oikkonen, 1994 Finland | 2 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | ECCE | 47 | Oral
Oikkonen, 1994 Finland | 2 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell Can't tell | No | ECCE | 47 | Oral
Oikkonen, 1994 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | ECCE | 47 | Oral
Oikkonen, 1994 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell | No | ECCE | 47 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 1 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | ECCE | 46 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 1 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell Can't tell | No | ECCE | 46 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | ECCE | 46 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell Can't tell | No | Can't tell | 46 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 2 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell Can't tell | No | ECCE | 46 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 2 | Peribulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | Can't tell | 46 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Bupivacaine | | Can't tell Can't tell | No | Can't tell | 46 | Oral
Oikkonen, Heine, Salminen et al., 1994 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified Subconjunctival No details | Lidocaine | | Can't tell Can't tell | No | ECCE | 46 | Oral
Oikkonen and Reinikainen, 1996 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 1 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 1 | Subconjunctival | Bupivacaine | | <4cc | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 1 | Subconjunctival | Lidocaine | | <4cc | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 2 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 2 | Subconjunctival | Bupivacaine | | <4cc | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 2 | Subconjunctival | Lidocaine | | <4cc | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 3 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 3 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 3 | Subconjunctival | Bupivacaine | | <4 cc | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 3 | Subconjunctival | Lidocaine | | <4 cc | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 4 | Retrobulbar Can't tell Can't tell Not specified | Bupivacaine | | <4 cc Can't tell | | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 4 | Retrobulbar Can't tell Can't tell Not specified | Lidocaine | | <4 cc Can't tell | | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 4 | Subconjunctival | Bupivacaine | | <4 cc | Can't tell | Can't tell | | Oral
Oikkonen and Reinikainen, 1996 Finland | 4 | Subconjunctival | Lidocaine | | <4 cc | Can't tell | Can't tell | | Oral
Pac-Soo, Deacock, Lockwood et al., 1996 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | 44 | IV other
Pac-Soo, Deacock, Lockwood et al., 1996 UK | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | 44 | IV other
Pac-Soo, Deacock, Lockwood et al., 1996 UK | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | 40 | IV benzodiazepines
Pac-Soo, Deacock, Lockwood et al., 1996 UK | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | 40 | IV benzodiazepines
Pac-Soo, Deacock, Lockwood et al., 1996 UK | 3 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | 43 | IV propofol
Pac-Soo, Deacock, Lockwood et al., 1996 UK | 3 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | 43 | IV propofol
Rosenberg, Raymond, and Bridge, 1995 USA | 1 | Peribulbar Can't tell Can't tell | | | Can't tell | No | Can't tell | | IV barbiturates
Rosenberg, Raymond, and Bridge, 1995 USA | 2 | Peribulbar Can't tell Can't tell | | | Can't tell | No | Can't tell | | IV benzodiazepines
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 26 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 26 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 30 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 30 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 3 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 30 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 3 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 30 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 4 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 26 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 4 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 26 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 5 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 30 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | 5 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | Can't tell | 30 | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | 1 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | ECCE | | Placebo
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | 1 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | ECCE | | Placebo
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | ECCE | | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | 2 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | ECCE | | IV other
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | 3 | Peribulbar Can't tell Can't tell Not specified | Lidocaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | ECCE | | IV benzodiazepines
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | 3 | Peribulbar Can't tell Can't tell Not specified | Bupivacaine | Hyaluronidase Epinephrine | 4-6 cc Can't tell | No | ECCE | | IV benzodiazepines
Yee, Burns, Mann et al., 1996 USA | 1 | Retrobulbar Can't tell 23g Blunt | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV propofol
Yee, Burns, Mann et al., 1996 USA | 1 | Retrobulbar Can't tell 23g Blunt | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV propofol
Yee, Burns, Mann et al., 1996 USA | 2 | Retrobulbar Can't tell 23g Blunt | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Yee, Burns, Mann et al., 1996 USA | 2 | Retrobulbar Can't tell 23g Blunt | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Yee, Burns, Mann et al., 1996 USA | 3 | Retrobulbar Can't tell 23g Blunt | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Yee, Burns, Mann et al., 1996 USA | 3 | Retrobulbar Can't tell 23g Blunt | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Yee, Burns, Mann et al., 1996 USA | 4 | Retrobulbar Can't tell 23g Blunt | Lidocaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Yee, Burns, Mann et al., 1996 USA | 4 | Retrobulbar Can't tell 23g Blunt | Bupivacaine | Hyaluronidase | 4-6 cc Can't tell | No | Can't tell | | IV analgesics IV propofol
Yee, Schafer, Crandall et al., 1994 USA | 1 | Retrobulbar No details | | | | No | Can't tell | | IV barbiturates
Yee, Schafer, Crandall et al., 1994 USA | 2 | Retrobulbar No details | | | | No | Can't tell | | IV analgesics

Evidence Table 3. Methodologic quality of literature on anesthesia for cataract surgery

Author(s), year, and country of study | Exclusion criteria | Quality score
Author(s), year, and country of study | Exclusion criteria | Representativeness, questions 12-15 (percent) | Bias, questions 17-19 (percent) | Description of therapy, questions 20-24 (percent) | Outcomes, questions 25-28 (percent) | Statistical quality, questions 29-32 (percent) | Overall quality score (percent)
(1) Main Topic: Regional Anesthesia
Abelson, Mandel, Paradis et al., 1989 USA | None stated, consecutive | 50 | 50 | 23 | 55 | 50 | 46
Agrawal and Athanikar, 1994 India | None stated | 13 | N/A | 71 | 60 | N/A | 43
Ali-Melkkila, Virkkila, Leino et al., 1993 Finland | None stated | 25 | 75 | 46 | 75 | 67 | 58
Anderson, 1995 USA | None stated, consecutive | 19 | N/A | 43 | 50 | N/A | 37
Anderson, Nath, and Anderson, 1999 USA | One refusal, one with severe head nodding | 81 | 67 | 69 | 65 | 50 | 66
Athanikar and Agrawal, 1991 India | None stated | 0 | 58 | 15 | 65 | 13 | 30
Bell and Butt, 1995 UK | None stated | 19 | 42 | 15 | 55 | 50 | 36
Bjornstrom, Hansen, Otland et al., 1994 Denmark | Patients with ocular comorbidity | 13 | 33 | 15 | 50 | 38 | 30
Briggs, Beck, and Esakowitz, 1997 UK | None stated | 19 | 0 | 8 | 65 | 38 | 26
Buttery and Wise, 1989 Australia | None stated, consecutive | 13 | 42 | 46 | 60 | 50 | 42
Carino, Slomovic, Chung et al., 1998 Canada | Dementia, confusion | 56 | 42 | 46 | 70 | 50 | 53
Chittenden, Meacock, and Govan, 1997 UK | None stated | 0 | 17 | 38 | 65 | 50 | 34
Corboy and Jiang, 1997 USA | None stated | 38 | N/A | 14 | 40 | N/A | 31
Crandall, Zabriskie, Patel et al., 1999 USA | Monocular, ASA >3 | 25 | 67 | 46 | 75 | 18 | 46
Davis and Mandel, 1986 USA | None stated | 0 | N/A | 29 | 10 | N/A | 13
Davis and O'Connor, 1989 Canada | None stated, consecutive patients | 67 | 67 | 46 | 60 | 25 | 53
Demirok, Simsek, Cinal et al., 1997 Turkey | None stated | 6 | 33 | 15 | 60 | 50 | 33
Dinsmore, 1995 USA | None stated, consecutive patients | 67 | N/A | 43 | 25 | N/A | 34
Dinsmore, 1996 USA | None stated | 75 | N/A | 57 | 20 | N/A | 38
Dopfmer, Maloney, Gaynor et al., 1996 Germany | None stated | 19 | 67 | 23 | 70 | 38 | 43
Edge, McClarty, Krige et al., 1995 Saudi Arabia | Eye disease other than cataract | 31 | 33 | 15 | 55 | 25 | 32
Ellingsson and Aasved, 1979 Norway | None stated | 6 | 25 | 38 | 20 | 13 | 20
Feibel, Custer, and Gordon, 1993 USA | Ocular comorbidity | 75 | 100 | 15 | 70 | 67 | 65
Fukasaku and Marron, 1994 Japan | None stated | 13 | 18 | 8 | 20 | 0 | 11
Furuta, Toriumi, Kashiwagi et al., 1990 Japan | Posterior synechiae, mental disorders, postvitrectomy cataracts | 75 | N/A | 71 | 30 | N/A | 59
Garcia, Loureiro, Limao et al., 1998 Portugal | High preoperative IOP, complicated surgery | 19 | 17 | 38 | 70 | 50 | 39
Gillart, Bazin, Deret et al., 1996 France | None stated | 25 | 100 | 31 | 60 | 50 | 53
Gillart, Bazin, Montetagaud et al., 1998 France | None stated | 31 | 42 | 46 | 80 | 50 | 50
Gills, Cherchio, and Raanan, 1997 USA | Known allergy to topical anesthetics | 56 | 67 | 46 | 70 | 38 | 55
Guise, 1996 New Zealand | None stated | 13 | N/A | 14 | 50 | N/A | 26
Gutman, Sinskey, and Cain, 1979 USA | History of monoamine oxidase inhibitor use | 50 | 17 | 23 | 55 | 25 | 34
Hamilton and Claoue, 1998 UK | No exclusion | 38 | 0 | 46 | 60 | 50 | 39
Hamilton, Gimbel, and Strunin, 1988 Canada | None reported. | 50 | 0 | 23 | 60 | 25 | 32
Henderson and Franks, 1996 UK | None stated, consecutive | 13 | 67 | 15 | 40 | 50 | 37
Hendrick, Rosenberg, and Lebenbom-Mansour, 1997 USA | None stated, consecutive patients | 100 | N/A | 86 | 40 | N/A | 75
Hinshaw, Fiscella, and Sugar, 1995 USA | Diabetes, cardiac medications | 25 | 50 | 15 | 60 | 38 | 38
Hodgkins, Teye-Botchway, Morrell et al., 1992 UK | Incomplete followup | 81 | N/A | 29 | 40 | N/A | 61
Hosal, Tekeli, and Gursel, 1998 Turkey | Patients with thyroid eye disease, external eye disease, and prior lid surgery | 44 | N/A | 29 | 70 | N/A | 44
House, Hollands, and Schulzer, 1991 Canada | None stated, consecutive patients | 50 | 67 | 57 | 45 | 38 | 51
Huha, Ala-Kokko, Salomaki et al., 1999 Finland | None stated | 38 | 83 | 46 | 65 | 67 | 60
Johansen, Kjeldgard, and Corydon, 1993 Denmark | Patients with ocular comorbidity and retrobulbar hemorrhage | 50 | 33 | 18 | 15 | 25 | 28
John, 1998 USA | None stated | 6 | 0 | 46 | 20 | 0 | 14
Johnston, Whitefield, Giralt et al., 1998 UK | Claustrophobia, orthoptera, nystagmus | 13 | 0 | 38 | 30 | 50 | 26
Jolliffe, Abdel-Khalek, and Norton, 1997 UK | Prior operations, oral anesthetic, nonspecific anesthetic, or surgical variables | 50 | 50 | 64 | 60 | 27 | 50
Joyce, Sunderraj, Villada et al., 1994 UK | None stated | 6 | 42 | 71 | 45 | 50 | 43
Kaplan, Jaffe, and Clayman, 1985 USA | None stated | 69 | 25 | 8 | 70 | 17 | 38
Kapran, Uyar, Eltutar et al., 1996 Turkey | Corneal lacerations | 25 | 17 | 15 | 70 | 0 | 25
Kershner, 1993 USA | Not reported | 0 | N/A | 43 | 50 | N/A | 23
Khoo, Lim, and Yong, 1996 Singapore | None stated, consecutive patients | 75 | 42 | 15 | 60 | 38 | 46
Khurana, Sachdeva, Gombar et al., 1994 India | None stated, consecutive patients | 50 | 17 | 15 | 45 | 25 | 30
Kishore, Agarwal, Sood et al., 1990 India | None stated | 25 | N/A | 57 | 70 | N/A | 55
Koch, 1997 USA | Preoperative sedation | 56 | N/A | 71 | 35 | N/A | 54
Kollarits, Jaweed, and Kollarits, 1998 USA | Oral/IV sedation | 13 | 0 | 23 | 55 | 0 | 18
Kothari, Shah, Shah et al., 1998 India | None stated, consecutive patients | 31 | N/A | 14 | 40 | N/A | 29
Krause, Weindler, and Ruprecht, 1997 Germany | Prior ocular surgery, axial length greater than 26 mm | 31 | 42 | 15 | 70 | 50 | 42
Krohn, Seland, Hovding et al., 1993 Norway | Patients with ocular comorbidity and contraindications to adrenalin | 44 | 50 | 38 | 60 | 38 | 46
Kumar, Bose, Bhattacharya et al., 1992 India | ASA >=3 | 63 | 100 | 62 | 50 | 50 | 65
Lewis, Hamilton, Brant et al., 1992 Canada | Patients with prior vitreoretinal surgery | 25 | 50 | 31 | 55 | 25 | 37
Loots, Koorts, and Venter, 1993 South Africa | None reported | 0 | 50 | 86 | 55 | 33 | 45
Maclean, Burton, and Murray, 1997 UK | 10 patients for inability to understand VAS | 69 | 33 | 77 | 70 | 67 | 63
Manners and Burton, 1996 UK | Prior ocular surgery or injury | 69 | 17 | 38 | 60 | 38 | 44
Masket and Gokmen, 1998 USA | Incomplete chart | 63 | 0 | 15 | 65 | 18 | 32
Mindel, 1978 USA | Organic brain disease, preexisting extraocular muscle paralysis | 25 | 33 | 15 | 50 | 50 | 35
Morsman and Holden, 1992 Finland | None stated, consecutive patients | 31 | 17 | 31 | 30 | 50 | 32
Muller, Claasen, Schall et al., 1996 South Africa | None stated | 19 | 42 | 14 | 45 | 50 | 34
Murdoch, 1990 UK | None stated | 58 | 33 | 23 | 70 | 38 | 44
Nathan, Benrhaiem, Lotfi et al., 1996 France | History of bleeding, cardiac, hepatic, and renal failure | 38 | 50 | 38 | 10 | 67 | 41
Nielsen, 1995 Denmark | None stated, consecutive | 0 | 0 | 10 | 40 | 67 | 23
Nielsen and Allerod, 1998 Denmark | Consecutive patients, 1 excluded for vasovagal episode | 50 | 67 | 69 | 40 | 67 | 59
Nolan, Aziz, Ahmad et al., 1993 Ireland | None stated, consecutive | 31 | 0 | 46 | 30 | 0 | 21
Ortiz, Blanco, Serra et al., 1995 Spain | None stated | 25 | 50 | 14 | 35 | 17 | 28
Pappa, Pouliou, Nastou et al., 1995 Greece | None stated | 0 | 42 | 14 | 45 | 38 | 28
Patel, Burns, Crandall et al., 1996 USA | None stated, consecutive | 88 | 33 | 54 | 50 | 38 | 52
Patel, Clinch, Burns et al., 1998 USA | Anticoagulation | 50 | 33 | 54 | 70 | 38 | 49
Pecka and Dexter, 1997 USA | 40 missing records | 100 | N/A | 67 | 0 | N/A | 56
Petersen and Yanoff, 1991 USA | None stated, consecutive | 0 | N/A | 14 | 20 | N/A | 9
Prosser, Rodney, Mian et al., 1996 UK | Prior anticoagulants use | 63 | 100 | 31 | 50 | 38 | 56
Redmond and Dallas, 1990 UK | Retrobulbar hemorrhage | 6 | 0 | 0 | 10 | 0 | 5
Roman, Auclin, and Ullern, 1996 France | None stated | 25 | 17 | 23 | 80 | 33 | 36
Roper and Nisbet, 1978 USA | Inadequate followup, ocular comorbidity | 25 | 50 | 0 | 40 | 13 | 26
Ropo, Ruusuvaara, Paloheimo et al., 1990 Finland | None stated, consecutive | 19 | 17 | 31 | 80 | 38 | 37
Ruusuvaara, Setala, Pajari et al., 1995 Finland | None stated | 0 | 17 | 8 | 55 | 0 | 16
Sanchez-Capuchino, Meadows, and Morgan, 1993 UK | None stated | 6 | 33 | 38 | 70 | 38 | 37
Sanders, Ahmed, Craig et al., 1997 UK | Prior ocular surgery for ophthalmic disease | 0 | 17 | 8 | 60 | 13 | 19
Sarvela, 1993 Finland | None stated, consecutive | 38 | 83 | 77 | 50 | 50 | 60
Sarvela and Nikki, 1992a Finland | None stated | 13 | 42 | 54 | 30 | 50 | 38
Sarvela and Nikki, 1992b Finland | None stated, consecutive patients | 88 | 17 | 31 | 70 | 38 | 48
Sarvela, Nikki, and Paloheimo, 1993 Finland | None stated | 6 | 50 | 46 | 60 | 38 | 40
Sarvela, Paloheimo, and Nikki, 1994 Finland | None stated | 38 | 83 | 62 | 70 | 38 | 58
Saunders, Sturgess, Pemberton et al., 1993 UK | None stated | 6 | 33 | 46 | 70 | 25 | 36
Schimek, Steuhl, and Fahle, 1993 Germany | Bulbar motility > 2 mm 20 minutes after retrobulbar block. | 13 | 50 | 15 | 60 | 38 | 35
Scott, Jakeman, Perry et al., 1995 UK | None stated | 13 | 0 | 8 | 70 | 13 | 21
Shammas, Milkie, and Yeo, 1997 USA | ASA >= 4, small pupil | 31 | 25 | 77 | 50 | 33 | 43
Shibata, Inage, Takayama et al., 1993 Japan | None stated | 13 | 17 | 0 | 30 | 0 | 12
Smith and Kim, 1980 USA | Known hypersensitivity to amide anesthetics | 0 | 17 | 31 | 50 | 0 | 19
Smith and Smith, 1983 USA | Extensive medical comorbidity, psychiatric medication use | 44 | 67 | 54 | 60 | 50 | 55
Smith, Kemp, and Smith 1987 USA | Drug sensitivity, extensive comorbidity, antidepressant use | 19 | 50 | 15 | 50 | 38 | 34
Sunderraj, Kirby, Joyce et al., 1991 UK | None reported | 25 | 42 | 31 | 65 | 50 | 42
Suzuki, Kuroki, and Fujiwara, 1997 Japan | Preexisting ocular disease | 38 | 50 | 62 | 60 | 50 | 52
Sweeney, Barber, and Prosser, 1993 Australia | None stated, consecutive | 25 | 0 | 46 | 40 | 50 | 32
Thomson, 1988 Ghana | No exclusions | 50 | 33 | 31 | 40 | 25 | 36
Thorburn, Thorn-Alquist, and Edstrom, 1976 Sweden | Uncooperative patients | 6 | 25 | 38 | 60 | 25 | 31
Tseng and Chen, 1998 Taiwan | Dementia, movement disorder, ocular conditions precluding lid block | 69 | 50 | 15 | 60 | 67 | 52
Ursell and Spalton, 1996 UK | Language or memory impairment | 31 | 42 | 71 | 50 | 50 | 49
Uusitalo, Maunuksela, Paloheimo et al., 1999 Finland | No exclusions | 69 | 67 | 46 | 80 | 27 | 58
Vettese and Breslin, 1985 Canada | Not mentioned | 0 | 50 | 15 | 50 | 38 | 31
Virtanen and Huha, 1998 Finland | Very hard cataract, previous glaucoma surgery | 44 | 33 | 23 | 60 | 67 | 45
Waller, Taboada, and O'Connor, 1993 USA | None stated | 0 | N/A | 0 | 30 | N/A | 10
Weiss and Deichman, 1989 USA | No exclusions | 50 | 42 | 62 | 75 | 50 | 56
Whitsett, Balyeat, and McClure, 1990 USA | None stated | 0 | 42 | 15 | 40 | 13 | 22
Wolf, Lynch, and Berlin, 1975 USA | None stated | 38 | N/A | 0 | 10 | N/A | 12
Wong, Koehrer, Sutton et al., 1993 Canada | No patients excluded | 88 | 83 | 31 | 75 | 50 | 65
Zehetmayer, Radax, Skorpik et al., 1996 Austria | Diabetes, glaucoma, previous eye surgery, uncooperative patient | 88 | 100 | 31 | 80 | 44 | 69
Zehetmayer, Rainer, Turnheim et al., 1997 Austria | Diabetes, patients with glaucoma, previous eye surgery, anxious, uncooperative patients. | 44 | 50 | 77 | 75 | 38 | 57
(2) Main Topic: Regional Anesthesia and Sedation
Boezaart, Berry, Laubscher et al., 1998 South Africa | Patients not requesting anxiolytic therapy | 88 | 83 | 46 | 70 | 67 | 71
Cruise, Chung, Yogendran et al., 1997 Canada | None stated | 63 | 92 | 15 | 50 | 50 | 54
el-Bassiouny, el-Taher, and el-Din, 1992 Egypt | Severe systemic disease, drug sensitivities, and elevated intraocular pressure | 88 | 67 | 77 | 70 | 67 | 74
Mjahed, el Harrar, Hamdani et al., 1996 Morocco | High intraocular pressure, preoperative cardiovascular medication use | 25 | 50 | 46 | 60 | 50 | 46
Wong and Merrick, 1996 Canada | Dementia, monocular patients, significant pulmonary disease, and use of beta blocker | 75 | 100 | 46 | 75 | 67 | 73
(3) Main Topic: Sedation
Chung, Cheng, Seyone et al., 1990 Canada | Allergy to benzodiazepines, emulsion, fentanyl; clinically significant disease; psychotropic medication use; impaired mental function; inability to function or read with unoperated eye | 63 | 92 | 23 | 75 | 50 | 60
Coley, Jones, Lassey et al., 1990 UK | ASA >3, patients with known sensitivity to opioids, Parkinsonism, or markedly increased IOP | 75 | 83 | 69 | 90 | 67 | 71
Cugini, Lanzetta, Nadbath et al., 1997 Italy | Age < 65, ocular surgery or medications | 44 | 25 | 31 | 70 | 33 | 41
Filos, Patroni, Goudas et al., 1993 Greece | Myocardial infarction <12 months; ischemic charges in electrocardiogram, diastolic BP >100 mmHg; h/o uveitis; glaucoma or previous ocular surgery; preoperative IOP >22 mmHg; clonidine use | 63 | 100 | 15 | 60 | 75 | 63
Gilbert, Holt, Johnston et al., 1987 USA | Sensitivity to study drugs, a history of hepatic or renal disease, receiving narcotic, psychotropic or narcotic drugs | 88 | 92 | 46 | 75 | 33 | 67
Herrick, Gelb, Nichols et al., 1996 Canada | None stated | 50 | 50 | 69 | 70 | 67 | 61
Ibrahim and Savino, 1974 USA | No exclusions | 75 | 50 | 69 | 45 | 13 | 50
Karhunen and Orko, 1981 Finland | None stated | 19 | 17 | 46 | 65 | 25 | 34
Khalil, Howard, Mankarious et al., 1998 USA | None stated | 38 | 100 | 46 | 55 | 67 | 61
Kost and Emerson, 1992 USA | Mental retardation, ASA >=4 | 63 | 33 | 46 | 75 | 25 | 48
Kumar, Tandon, Bhattacharya et al., 1994 India | Patients receiving clonidine, beta blockers or calcium channel blocker | 50 | 83 | 69 | 60 | 67 | 66
Michelson and Naujoks, 1991 Germany | None stated | 38 | 50 | 46 | 50 | 0 | 37
Oikkonen, 1994 Finland | None stated, consecutive patients | 75 | 67 | 31 | 50 | 33 | 51
Oikkonen, Heine, Salminen et al., 1994 Finland | Psychiatric medications or illnesses, age >70 | 75 | 67 | 54 | 70 | 33 | 60
Oikkonen and Reinikainen, 1996 Finland | Digitalis medication, intraventricular conduction abnormalities, left ventricular strain, atrial fibrillation/flutter | 63 | 67 | 46 | 70 | 67 | 62
Pac-Soo, Deacock, Lockwood et al., 1996 UK | Age >85, cardiopulmonary disease | 50 | 92 | 54 | 70 | 50 | 63
Rosenberg, Raymond, and Bridge, 1995 USA | None stated | 0 | 25 | 15 | 60 | 33 | 27
Virkkila, Ali-Melkkila, and Kanto, 1992 Finland | Neuropsychiatric medications | 75 | 92 | 77 | 70 | 67 | 76
Virkkila, Ali-Melkkila, Kanto et al., 1993 Finland | None stated | 25 | 92 | 77 | 75 | 50 | 64
Virkkila, Ali-Melkkila, Kanto et al., 1994 Finland | None stated | 63 | 75 | 46 | 75 | 50 | 62
Yee, Burns, Mann et al., 1996 USA | None stated | 38 | 67 | 23 | 75 | 67 | 54
Yee, Schafer, Crandall et al., 1994 USA | None stated | 19 | 67 | 15 | 70 | 50 | 44

Evidence Table 4. Local anesthesia: Is there evidence that a retrobulbar block is more effective at producing akinesia than a peribulbar block?

Author(s)/year | Study aim | Group | # subjects | Block type | Agent(s) used | % complete akinesia | % poor akinesia | Comments on akinesia
Ali-Melkkila, Virkkila, Leino et al., 1993 | To compare the effectiveness of two methods of peribulbar anesthesia with retrobulbar anesthesia. | 1 | 150 | Retrobulbar | Lidocaine Bupivacaine | 71 | 12
Ali-Melkkila, Virkkila, Leino et al., 1993 | To compare the effectiveness of two methods of peribulbar anesthesia with retrobulbar anesthesia. | 2 | 150 | Peribulbar | Lidocaine Bupivacaine | 72 | 19
Ali-Melkkila, Virkkila, Leino et al., 1993 | To compare the effectiveness of two methods of peribulbar anesthesia with retrobulbar anesthesia. | 3 | 150 | Peribulbar | Bupivacaine Lidocaine | 75 | 11
Athanikar and Agrawal, 1991 | To compare the effectiveness of peribulbar anesthesia to retrobulbar anesthesia. | 1 | 71 | Retrobulbar | Lidocaine | 79
Athanikar and Agrawal, 1991 | To compare the effectiveness of peribulbar anesthesia to retrobulbar anesthesia. | 2 | 71 | Peribulbar | Lidocaine | 77
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 1 | 51 | Subconjunctival | Bupivacaine Lidocaine | | 20
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 1 | 51 | Retrobulbar | Bupivacaine Lidocaine | | 20
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 2 | 48 | Peribulbar | Bupivacaine Lidocaine | | 6
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 1 | 42 | Retrobulbar | Bupivacaine | | | Lid akinesia included in scoring of globe akinesia. No significant difference in total akinesia scores of Group 1 versus Group 2.
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 2 | 43 | Peribulbar | Bupivacaine | | | Lid akinesia included in scoring of globe akinesia. No significant difference in total akinesia scores of Group 1 versus Group 2.
Weiss and Deichman, 1989 | To compare the safety and effectiveness of retrobulbar and periocular anesthesia. | 1 | 40 | Retrobulbar | Lidocaine Bupivacaine | | | Globe akinesia reported as mean values. For both groups akinesia was good, without significant between-group differences. (OR time in minutes not reported by group)
Weiss and Deichman, 1989 | To compare the safety and effectiveness of retrobulbar and periocular anesthesia. | 2 | 39 | Peribulbar | Bupivacaine Lidocaine
Whitsett, Balyeat, and McClure, 1990 | To compare peribulbar and retrobulbar anesthesia. | 1 | 50 | Peribulbar | Lidocaine Bupivacaine | | | There was no significant difference between groups.
Whitsett, Balyeat, and McClure, 1990 | To compare peribulbar and retrobulbar anesthesia. | 2 | 50 | Retrobulbar | Bupivacaine Lidocaine
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 1 | 50 | Retrobulbar | Bupivacaine Lidocaine | | 26
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 2 | 50 | Peribulbar | Bupivacaine Lidocaine | | 10
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 3 | 50 | Retrobulbar | Lidocaine Bupivacaine | | 8

Evidence Table 5. Local anesthesia: Is there evidence that a retrobulbar block is more effective at producing akinesia than a subconjunctival/sub-Tenon's block?

Author(s)/year | Study aim | Group | # subjects | Block type | Agent(s) used | % complete akinesia | % poor akinesia | Comments on akinesia
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of subconjunctival/sub-Tenon's and retrobulbar anesthesia. | 1 | 270 | Retrobulbar | Bupivacaine Lidocaine | 41 | 7
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of subconjunctival/sub-Tenon's and retrobulbar anesthesia. | 2 | 300 | Subconjunctival | Lidocaine Bupivacaine | 69 | 1
Khoo, Lim, and Yong, 1996 | To compare the effectiveness of subconjunctival/sub-Tenon's with retrobulbar anesthesia. | 1 | 55 | Subconjunctival | Lidocaine | | 4 | 2 of 55 patients in sub-Tenon's group had residual movement affecting surgery.
Khoo, Lim, and Yong, 1996 | To compare the effectiveness of subconjunctival/sub-Tenon's with retrobulbar anesthesia. | 2 | 51 | Retrobulbar | Lidocaine | | 0

Evidence Table 6. Local anesthesia: Is there evidence that a peribulbar block is more effective at producing akinesia than a subconjuctival/sub-Tenon's block?

Author(s)/year | Study aim | Group | # subjects | Block type | Agent(s) used | % complete akinesia | % poor akinesia | Comments on akinesia
Khurana, Sachdeva, Gombar et al., 1994 | To compare the effectiveness of peribulbar with subconjunctival/sub-Tenon's anesthesia. | 1 | 100 | Peribulbar | Lidocaine Bupivacaine | 85 | 6
Khurana, Sachdeva, Gombar et al., 1994 | To compare the effectiveness of peribulbar with subconjunctival/sub-Tenon's anesthesia. | 2 | 100 | Subconjunctival | Lidocaine Bupivacaine | 52 | 19
Kollarits, Jaweed, and Kollarits, 1998 | To compare the effectiveness of peribulbar and subconjunctival/sub-Tenon's anesthesia. | 1 | 100 | Peribulbar | Lidocaine | 82 | | Akinesia was assessed at the completion of surgery.
Kollarits, Jaweed, and Kollarits, 1998 | To compare the effectiveness of peribulbar and subconjunctival/sub-Tenon's anesthesia. | 2 | 100 | Subconjunctival | Lidocaine | 80 | 9

Evidence Table 7. Local anesthesia: Is there evidence of the effectiveness of a peribulbar block at producing akinesia?

Author(s)/year | Study aim | Group | # subjects | Block type | Agent(s) used | % complete akinesia | % poor akinesia | Comments on akinesia
Agrawal and Athanikar, 1994 | To report the effectiveness of single-injection, low-volume, periocular anesthesia. | 1 | 1,000 | Peribulbar | Lidocaine | 75 | 2
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 1 | 27 | Peribulbar | Bupivacaine Lidocaine | 78 | | 7 eyes with some ocular motility.
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 2 | 27 | Peribulbar | Bupivacaine Lidocaine | 26 | | 18 eyes with some ocular motility.
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 1 | 54 | Peribulbar | Lidocaine | | 6 | 94/100 patients had a successful initial block.
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 2 | 46 | Peribulbar | Bupivacaine Lidocaine | | 7
Demirok, Simsek, Cinal et al., 1997 | To compare the effectiveness of one versus two injections of peribulbar anesthesia. | 1 | 57 | Peribulbar | Bupivacaine Lidocaine | | | Both groups had equivalent akinesia scores (3.5 vs. 3.1, full movement=12) at 10 minutes after injection.
Demirok, Simsek, Cinal et al., 1997 | To compare the effectiveness of one versus two injections of peribulbar anesthesia. | 2 | 63 | Peribulbar | Bupivacaine Lidocaine
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 1 | 46 | Peribulbar | Bupivacaine Lidocaine | 26 | | Median ocular movement score at 8 minutes was 3.
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 2 | 44 | Peribulbar | Prilocaine | 61 | | Median ocular movement score at 8 minutes was 1.
Gillart, Bazin, Deret et al., 1996 | To assess the effect of the pressure on injection of local anesthesia during peribulbar block. | 1 | 25 | Peribulbar | Bupivacaine Etidocaine | 28 | 72 | Akinesia was assessed by both EOM movement and lid movement. There was significant difference for eyelid akinesia (19 had complete akinesia).
Gillart, Bazin, Deret et al., 1996 | To assess the effect of the pressure on injection of local anesthesia during peribulbar block. | 2 | 25 | Peribulbar | Bupivacaine Etidocaine | 72 | 28 | 20 had complete akinesia.
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 1 | 35 | Peribulbar | Bupivacaine Lidocaine | 40
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 2 | 35 | Peribulbar | Bupivacaine Lidocaine | 60
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 3 | 35 | Peribulbar | Bupivacaine Lidocaine | 54
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 4 | 35 | Peribulbar | Lidocaine Bupivacaine | 83
Hamilton, Gimbel, and Strunin, 1988 | To assess the safety and effectiveness of 12,000 regional anesthetics administered by one doctor using 5 different techniques of injection anesthesia. | 3 | 3,478 | Peribulbar | Bupivacaine Lidocaine | 83 | 5
Hamilton, Gimbel, and Strunin, 1988 | To assess the safety and effectiveness of 12,000 regional anesthetics administered by one doctor using 5 different techniques of injection anesthesia. | 4 | 2,226 | Peribulbar | Lidocaine Bupivacaine | 84 | 4
Hamilton, Gimbel, and Strunin, 1988 | To assess the safety and effectiveness of 12,000 regional anesthetics administered by one doctor using 5 different techniques of injection anesthesia. | 5 | 1,061 | Peribulbar | Lidocaine Bupivacaine | 90 | 3
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 1 | 41 | Peribulbar | Prilocaine | | | Mean of akinesia score (0-6 scale) prilocaine was 0.37.
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 2 | 34 | Peribulbar | Bupivacaine Lidocaine
Hendrick, Rosenberg, and Lebenbom-Mansour, 1997 | To report the effectiveness and safety of peribulbar block performed by anesthesiologists. | 1 | 1,074 | Peribulbar | Bupivacaine Lidocaine | 74
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 1 | 28 | Peribulbar | Lidocaine Bupivacaine | 96
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 2 | 15 | Peribulbar | Bupivacaine | 60
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 3 | 15 | Peribulbar | Bupivacaine Lidocaine | 47
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 4 | 13 | Peribulbar | Bupivacaine | 46
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 5 | 16 | Peribulbar | Bupivacaine | 44
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 6 | 15 | Peribulbar | Bupivacaine | 40
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 7 | 15 | Peribulbar | Lidocaine Bupivacaine | 33
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 1 | 50 | Peribulbar | Bupivacaine | 52
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 2 | 50 | Peribulbar | Ropivacaine | 32
Kishore, Agarwal, Sood et al., 1990 | To describe the effectiveness of a peribulbar anesthetic technique. | 1 | 106 | Peribulbar | Lidocaine Bupivacaine | 66 | 4
Kothari, Shah, Shah et al., 1998 | To evaluate the effectiveness of peribulbar injection supplemented by topical anesthesia. | 1 | 500 | Peribulbar | Lidocaine | 34 | 8
Lewis, Hamilton, Brant et al., 1992 | To assess the effectiveness of the pH adjustment of bupivacaine in peribulbar block. | 1 | 26 | Peribulbar | Bupivacaine | | 35
Lewis, Hamilton, Brant et al., 1992 | To assess the effectiveness of the pH adjustment of bupivacaine in peribulbar block. | 2 | 24 | Peribulbar | Bupivacaine | | 25
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anaesthesia. | 1 | 51 | Peribulbar | Bupivacaine | 39 | 61 | There was no significant difference in complete akinesia between Group 1 and Group 3.
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anaesthesia. | 2 | 50 | Peribulbar | Bupivacaine | 54 | 46
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anaesthesia. | 3 | 50 | Peribulbar | Lidocaine Bupivacaine | 54 | 46
Muller, Claasen, Schall et al., 1996 | To compare the effectiveness of two different bupivacaine hydrochloride products. | 1 | 52 | Peribulbar | Bupivacaine | | 10
Muller, Claasen, Schall et al., 1996 | To compare the effectiveness of two different bupivacaine hydrochloride products. | 2 | 48 | Peribulbar | Bupivacaine | | 10
Nathan, Benrhaiem, Lotfi et al., 1996 | To compare the pharmacokinetics of lidocaine and bupivacaine with and without hyaluronidase for peribulbar anesthesia. | 1 | 10 | Peribulbar | Lidocaine Bupivacaine | 80
Nathan, Benrhaiem, Lotfi et al., 1996 | To compare the pharmacokinetics of lidocaine and bupivacaine with and without hyaluronidase for peribulbar anesthesia. | 2 | 10 | Peribulbar | Bupivacaine Lidocaine | 80
Nolan, Aziz, Ahmad et al., 1993 | To compare the effectiveness of seven different block techniques as well as different agents. | 1 | 30 | Peribulbar | Lidocaine Bupivacaine | | 17 | Graded as satisfactory versus unsatisfactory.
Nolan, Aziz, Ahmad et al., 1993 | To compare the effectiveness of seven different block techniques as well as different agents. | 2 | 30 | Peribulbar | Lidocaine Bupivacaine | | 10
Nolan, Aziz, Ahmad et al., 1993 | To compare the effectiveness of seven different block techniques as well as different agents. | 3 | 30 | Peribulbar | Lidocaine Bupivacaine | | 17
Nolan, Aziz, Ahmad et al., 1993 | To compare the effectiveness of seven different block techniques as well as different agents. | 4 | 30 | Peribulbar | Lidocaine Bupivacaine | | 20
Nolan, Aziz, Ahmad et al., 1993 | To compare the effectiveness of seven different block techniques as well as different agents. | 5 | 30 | Peribulbar | Lidocaine Bupivacaine | | 27
Nolan, Aziz, Ahmad et al., 1993 | To compare the effectiveness of seven different block techniques as well as different agents. | 6 | 30 | Peribulbar | Bupivacaine Lidocaine | | 37
Nolan, Aziz, Ahmad et al., 1993 | To compare the effectiveness of seven different block techniques as well as different agents. | 7 | 30 | Peribulbar | Bupivacaine Lidocaine | | 40
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 1 | 30 | Peribulbar | Bupivacaine | | | Maximum score for each quadrant = 2. Also measured lid function for total score of 10. Any score >= 3 was a failure. Group 1 had 25 failures.
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 2 | 30 | Peribulbar | Bupivacaine | | | Group 2 had 14 failures.
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 3 | 30 | Peribulbar | Bupivacaine | | | Group 3 had 15 failures.
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 4 | 30 | Peribulbar | Bupivacaine | | | Group 4 had 12 failures.
Pac-Soo, Deacock, Lockwood et al., 1996 | To compare self-administered midazolam or propofol with saline for sedation and hemodynamic effect. | 1 | 26 | Peribulbar | Bupivacaine Lidocaine | | | There were no significant differences between groups with respect to akinesia.
Pac-Soo, Deacock, Lockwood et al., 1996 | To compare self-administered midazolam or propofol with saline for sedation and hemodynamic effect. | 2 | 24 | Peribulbar | Lidocaine Bupivacaine
Pac-Soo, Deacock, Lockwood et al., 1996 | To compare self-administered midazolam or propofol with saline for sedation and hemodynamic effect. | 3 | 25 | Peribulbar | Bupivacaine Lidocaine
Prosser, Rodney, Mian et al., 1996 | To assess the effectiveness of hyaluronidase in peribulbar anesthesia. | 1 | 25 | Peribulbar | Lidocaine Bupivacaine | 68 | 4
Prosser, Rodney, Mian et al., 1996 | To assess the effectiveness of hyaluronidase in peribulbar anesthesia. | 2 | 25 | Peribulbar | Bupivacaine Lidocaine | 84 | 4
Sarvela and Nikki, 1992b | To compare the effectiveness of a 31mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 1 | 48 | Peribulbar | Etidocaine | 79
Sarvela and Nikki, 1992b | To compare the effectiveness of a 31mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 2 | 49 | Peribulbar | Etidocaine | 94
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 1 | 35 | Peribulbar | Etidocaine | 43 | 14
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 2 | 35 | Peribulbar | Etidocaine | 77 | 3
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 3 | 40 | Peribulbar | Etidocaine | 98 | 0
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 4 | 40 | Peribulbar | Etidocaine | 98 | 3
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 1 | 40 | Peribulbar | Etidocaine | 80 | 20 | Akinesia of globe at 20 minutes.
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 2 | 40 | Peribulbar | Etidocaine | 78 | 23
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 3 | 40 | Peribulbar | Bupivacaine | 80 | 20
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 4 | 40 | Peribulbar | Bupivacaine | 38 | 63
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 1 | 31 | Peribulbar | Bupivacaine | | 16
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 2 | 30 | Peribulbar | Bupivacaine | | 23
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 3 | 29 | Peribulbar | Bupivacaine | | 34
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 4 | 30 | Peribulbar | Bupivacaine | | 17
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 1 | 39 | Peribulbar | Bupivacaine | 64 | | Akinesia assessed at 10 minutes after block.
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 2 | 43 | Peribulbar | Lidocaine Bupivacaine | 95
Scott, Jakeman, Perry et al., 1995 | To compare the effectiveness of a 16 mm versus a 25 mm needle for peribulbar anesthesia. | 1 | 36 | Peribulbar | Lidocaine Bupivacaine | | | Measured but not reported separately. Akinesia was sufficient to perform surgery without additional block in all patients.
Scott, Jakeman, Perry et al., 1995 | To compare the effectiveness of a 16 mm versus a 25 mm needle for peribulbar anesthesia. | 2 | 51 | Peribulbar | Bupivacaine Lidocaine
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 1 | 15 | Peribulbar | Mepivicaine | 100 | | Measured at conclusion of surgery.
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 2 | 14 | Peribulbar | Etidocaine | 100
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 3 | 16 | Peribulbar | Etidocaine | 94
Ursell and Spalton, 1996 | To assess the pain associated with peribulbar injection using room-temperature and warmed anesthetic agents. | 1 | 20 | Peribulbar | Lidocaine Bupivacaine | | | Adequate block in all 20.
Ursell and Spalton, 1996 | To assess the pain associated with peribulbar injection using room-temperature and warmed anesthetic agents. | 2 | 20 | Peribulbar | Lidocaine Bupivacaine
Virtanen and Huha, 1998 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | 1 | 51 | Peribulbar | Bupivacaine Lidocaine | 86 | 0
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 1 | 30 | Peribulbar | Lidocaine Bupivacaine | 100
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 2 | 30 | Peribulbar | Lidocaine Bupivacaine | 100
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 3 | 30 | Peribulbar | Lidocaine Bupivacaine | 100
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 4 | 30 | Peribulbar | Bupivacaine Lidocaine | 100

Evidence Table 8. Local anesthesia: Is there evidence of the effectiveness of a retrobulbar block at producing akinesia?

Author(s)/year | Study aim | Group | # subjects | Block type | Agent(s) used | % complete akinesia | % poor akinesia | Comments on akinesia
Abelson, Mandel, Paradis et al., 1989 | To assess the effectiveness of hyaluronidase in a local block. | 1 | 20 | Retrobulbar | Lidocaine Bupivacaine | 70 | 0
Abelson, Mandel, Paradis et al., 1989 | To assess the effectiveness of hyaluronidase in a local block. | 2 | 20 | Retrobulbar | Bupivacaine Lidocaine | 40 | 15
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 1 | 40 | Retrobulbar | Lidocaine Bupivacaine | 100
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 2 | 40 | Retrobulbar | Lidocaine Bupivacaine | 100
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 3 | 40 | Retrobulbar | Lidocaine Bupivacaine | 100
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 4 | 40 | Retrobulbar | Lidocaine Bupivacaine | 100
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 5 | 40 | Retrobulbar | Bupivacaine Lidocaine | 100
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 6 | 40 | Retrobulbar | Lidocaine Bupivacaine | 100
Buttery and Wise, 1989 | To compare the effectiveness of retrobulbar anesthesia using transdermal and transconjunctival technique. | 1 | 23 | Retrobulbar | Lidocaine | | | Akinesia assessed by 4-directional movement score. 2.86 score after 6 minutes. Akinesia equal at end of surgery.
Buttery and Wise, 1989 | To compare the effectiveness of retrobulbar anesthesia using transdermal and transconjunctival technique. | 2 | 25 | Retrobulbar | Lidocaine | | | 2.08 score after 6 minutes (p<0.05).
Ellingsson and Aasved, 1979 | To compare the effectiveness of etidocaine 1% versus lidocaine 2% using retrobulbar anesthesia. | 1 | 46 | Retrobulbar | Lidocaine | 93 | 4 | Akinesia included those with inadequate lid block.
Ellingsson and Aasved, 1979 | To compare the effectiveness of etidocaine 1% versus lidocaine 2% using retrobulbar anesthesia. | 2 | 22 | Retrobulbar | Etidocaine | 23 | 41
Ellingsson and Aasved, 1979 | To compare the effectiveness of etidocaine 1% versus lidocaine 2% using retrobulbar anesthesia. | 3 | 24 | Retrobulbar | Etidocaine | 67 | 21
Hamilton, Gimbel, and Strunin, 1988 | To assess the safety and effectiveness of 12,000 regional anesthetics administered by one doctor using 5 different techniques of injection anesthesia. | 1 | 3,595 | Retrobulbar | Lidocaine Bupivacaine | 90 | 4
Hamilton, Gimbel, and Strunin, 1988 | To assess the safety and effectiveness of 12,000 regional anesthetics administered by one doctor using 5 different techniques of injection anesthesia. | 2 | 1,640 | Retrobulbar | Bupivacaine Lidocaine | 91 | 3
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 1 | 34 | Retrobulbar | Bupivacaine Lidocaine | 74 | | Recorded as present or absent by surgeon.
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 2 | 31 | Retrobulbar | Lidocaine Bupivacaine | 68
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 3 | 37 | Retrobulbar | Lidocaine | 65
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 4 | 37 | Retrobulbar | Lidocaine | 62
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 1 | 35 | Retrobulbar | Bupivacaine Lidocaine | 77 | | No difference in mean akinesia scores.
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 2 | 35 | Retrobulbar | Bupivacaine Lidocaine | 60
Krohn, Seland, Hovding et al., 1993 | To assess the benefit of hyaluronidase in retrobulbar anesthesia. | 1 | 40 | Retrobulbar | Lidocaine | 83
Krohn, Seland, Hovding et al., 1993 | To assess the benefit of hyaluronidase in retrobulbar anesthesia. | 2 | 40 | Retrobulbar | Lidocaine | 93
Mindel, 1978 | To assess the benefit of hyaluronidase added to 2% mepivicaine for retrobulbar anesthesia. | 1 | 15 | Retrobulbar | Mepivicaine | 60 | | Stated that 2 patients had poor akinesia; did not name groups.
Mindel, 1978 | To assess the benefit of hyaluronidase added to 2% mepivicaine for retrobulbar anesthesia. | 2 | 12 | Retrobulbar | Mepivicaine | 75
Patel, Burns, Crandall et al., 1996 | To compare the effectiveness of topical anesthesia to retrobulbar anesthesia. | 2 | 69 | Retrobulbar | Lidocaine Bupivacaine | | 1
Patel, Clinch, Burns et al., 1998 | To assess the effectiveness of retrobulbar and topical anesthesia. | 2 | 45 | Retrobulbar | Lidocaine Bupivacaine | 93 | 2
Sanchez-Capuchino, Meadows, and Morgan, 1993 | To compare the effectiveness of retrobulbar anesthesia with and without facial block. | 1 | 25 | Retrobulbar | Prilocaine | 60 | 16
Sanchez-Capuchino, Meadows, and Morgan, 1993 | To compare the effectiveness of retrobulbar anesthesia with and without facial block. | 2 | 25 | Retrobulbar | Prilocaine | 84 | 4
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 1 | 40 | Retrobulbar | Etidocaine | 80 | 20 | Numbers are for akinesia of globe at 20 minutes.
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 2 | 40 | Retrobulbar | Etidocaine | 78 | 23 | Numbers are for akinesia of globe at 20 minutes.
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 3 | 40 | Retrobulbar | Bupivacaine | 80 | 20 | Numbers are for akinesia of globe at 20 minutes.
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 4 | 40 | Retrobulbar | Bupivacaine | 38 | 63 | Numbers are for akinesia of globe at 20 minutes.
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 1 | 31 | Retrobulbar | Bupivacaine | | 16
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 2 | 30 | Retrobulbar | Bupivacaine | | 23
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 3 | 29 | Retrobulbar | Bupivacaine | | 34
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 4 | 30 | Retrobulbar | Bupivacaine | | 17
Schimek, Steuhl, and Fahle, 1993 | To compare lidocaine, prilocaine, and mepivicaine, for retrobulbar block. | 1 | 30 | Retrobulbar | Lidocaine | | | Akinesia was measured by movement of each of the rectus muscles at specified times during the procedure and was reported as the mean percent that achieved normal motility at specified times. Mepivicaine had a statistically significantly longer duration.
Schimek, Steuhl, and Fahle, 1993 | To compare lidocaine, prilocaine, and mepivicaine, for retrobulbar block. | 2 | 30 | Retrobulbar | Prilocaine
Schimek, Steuhl, and Fahle, 1993 | To compare lidocaine, prilocaine, and mepivicaine, for retrobulbar block. | 3 | 30 | Retrobulbar | Mepivicaine
Smith and Kim, 1980 | To compare the effectiveness of lidocaine with etidocaine for retrobulbar block. | 1 | 25 | Retrobulbar | Lidocaine | | | Time of onset and duration reported. Etidocaine lasted longer, but both over 100 minutes for sensory anesthesia and motor block.
Smith and Kim, 1980 | To compare the effectiveness of lidocaine with etidocaine for retrobulbar block. | 2 | 25 | Retrobulbar | Etidocaine
Smith, Kemp, and Smith, 1987 | To compare the effectiveness of retrobulbar block with etidocaine versus a combination of lidocaine and bupivacaine. | 1 | 43 | Retrobulbar | Etidocaine | | | Measured by mean onset, was 1.5 minutes. Not statistically different.
Smith, Kemp, and Smith, 1987 | To compare the effectiveness of retrobulbar block with etidocaine versus a combination of lidocaine and bupivacaine. | 2 | 37 | Retrobulbar | Lidocaine Bupivacaine | | | Mean onset 1.1 minutes.
Thomson, 1988 | To assess the effectiveness of adding hyaluronidase to lidocaine in retrobulbar block. | 1 | 75 | Retrobulbar | Lidocaine | | | A single combined measurement for pain and anesthesia was given. Data cannot be separated. Successful regional block obtained with 92% of patients in hyaluronidase group and in 56% of no-hyaluronidase group.
Thomson, 1988 | To assess the effectiveness of adding hyaluronidase to lidocaine in retrobulbar block. | 2 | 75 | Retrobulbar | Lidocaine
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 1 | 15 | Retrobulbar | Mepivicaine | 100 | | Measured at conclusion of surgery.
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 2 | 14 | Retrobulbar | Etidocaine | 100
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 3 | 16 | Retrobulbar | Etidocaine | 94
Vettese and Breslin, 1985 | To compare the effectiveness of three different retrobulbar anesthetic block preparations. | 1 | 15 | Retrobulbar | Bupivacaine | 40 | 27
Vettese and Breslin, 1985 | To compare the effectiveness of three different retrobulbar anesthetic block preparations. | 2 | 15 | Retrobulbar | Bupivacaine Lidocaine | 40 | 33
Vettese and Breslin, 1985 | To compare the effectiveness of three different retrobulbar anesthetic block preparations. | 3 | 15 | Retrobulbar | Lidocaine Bupivacaine | 80 | 0

Evidence Table 9. Local anesthesia: Is there evidence of the effectiveness of a subconjunctival/sub-Tenon's block in producing akinesia?

Author(s)/year | Study aim | Group | # subjects | Block type | Agent(s) used | % complete akinesia | % poor akinesia | Comments on akinesia
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 1 | 54 | Subconjunctival | Lidocaine | | 6 | 94/100 patients had a successful initial block.
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 2 | 46 | Subconjunctival | Lidocaine Bupivacaine | | 7

Evidence Table 10. Local anesthesia: Is there evidence that adding hyaluronidase to local blocks produces better akinesia than not adding hyaluronidase?

Author(s)/year | Study aim | Group | # subjects | Agent(s) used | Hyaluronidase used? | % complete akinesia | % poor akinesia
Abelson, Mandel, Paradis et al., 1989 | To assess the effectiveness of hyaluronidase in a local block. | 1 | 20 | Lidocaine Bupivacaine | Yes | 70 | 0
Abelson, Mandel, Paradis et al., 1989 | To assess the effectiveness of hyaluronidase in a local block. | 2 | 20 | Lidocaine Bupivacaine | No | 40 | 15
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 1 | 27 | Lidocaine Bupivacaine | Yes | 78
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 2 | 27 | Bupivacaine Lidocaine | No | 26
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 1 | 28 | Lidocaine Bupivacaine | Yes | 96
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 2 | 15 | Bupivacaine | Yes | 60
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 3 | 15 | Bupivacaine Lidocaine | No | 47
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 4 | 13 | Bupivacaine | Yes | 46
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 5 | 16 | Bupivacaine | No | 44
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 6 | 15 | Bupivacaine | No | 40
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 7 | 15 | Lidocaine Bupivacaine | Yes | 33
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 1 | 34 | Lidocaine Bupivacaine | Yes | 74
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 2 | 31 | Bupivacaine Lidocaine | No | 68
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 3 | 37 | Lidocaine | Yes | 65
Johansen, Kjeldgard, and Corydon, 1993 | To compare the effectiveness of four different mixtures for retrobulbar anesthesia. | 4 | 37 | Lidocaine | No | 62
Krohn, Seland, Hovding et al., 1993 | To assess the benefit of hyaluronidase in retrobulbar anesthesia. | 1 | 40 | Lidocaine | Yes | 83
Krohn, Seland, Hovding et al., 1993 | To assess the benefit of hyaluronidase in retrobulbar anesthesia. | 2 | 40 | Lidocaine | No | 93
Mindel, 1978 | To assess the benefit of hyaluronidase added to 2% mepivicaine for retrobulbar anesthesia. | 1 | 15 | Mepivicaine | Yes | 60
Mindel, 1978 | To assess the benefit of hyaluronidase added to 2% mepivicaine for retrobulbar anesthesia. | 2 | 12 | Mepivicaine | No | 75
Nathan, Benrhaiem, Lotfi et al., 1996 | To compare the pharmacokinetics of lidocaine and bupivacaine with and without hyaluronidase for peribulbar anesthesia. | 1 | 10 | Bupivacaine Lidocaine | No | 80
Nathan, Benrhaiem, Lotfi et al., 1996 | To compare the pharmacokinetics of lidocaine and bupivacaine with and without hyaluronidase for peribulbar anesthesia. | 2 | 10 | Lidocaine Bupivacaine | Yes | 80
Prosser, Rodney, Mian et al., 1996 | To assess the effectiveness of hyaluronidase in peribulbar anesthesia. | 1 | 25 | Bupivacaine Lidocaine | No | 68 | 4
Prosser, Rodney, Mian et al., 1996 | To assess the effectiveness of hyaluronidase in peribulbar anesthesia. | 2 | 25 | Bupivacaine Lidocaine | Yes | 84 | 4
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 1 | 35 | Etidocaine | No | 43 | 14
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 2 | 35 | Etidocaine | Yes | 77 | 3
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 3 | 40 | Etidocaine | Yes | 98 | 0
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 4 | 40 | Etidocaine | Yes | 98 | 3
Sarvela, and Nikki, 1992b | To compare the effectiveness of a 31 mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 1 | 48 | Etidocaine | Yes | 79
Sarvela, and Nikki, 1992b | To compare the effectiveness of a 31 mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 2 | 49 | Etidocaine | Yes | 94
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 1 | 40 | Etidocaine | Yes | 80 | 20
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 2 | 40 | Etidocaine | Yes | 78 | 23
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 3 | 40 | Bupivacaine | Yes | 80 | 20
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 4 | 40 | Bupivacaine | Yes | 38 | 63
Thomson, 1988 | To assess the effectiveness of adding hyaluronidase to lidocaine in retrobulbar block. | 1 | 75 | Lidocaine | Yes
Thomson, 1988 | To assess the effectiveness of adding hyaluronidase to lidocaine in retrobulbar block. | 2 | 75 | Lidocaine | No

Evidence Table 11. Local anesthesia: Is there evidence that certain anesthetic agents used in local blocks produce better akinesia?

Author(s)/year | Study aim | Group | # subjects | Agent(s) used and concentration (%) | % complete akinesia | % poor akinesia
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 1 | 54 | Lidocaine 2% | | 6
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 2 | 46 | Bupivacaine 0.5% Lidocaine 2% | | 7
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lignocaine. | 1 | 46 | Lidocaine 2% Bupivacaine 0.75% | 26
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lignocaine. | 2 | 44 | Prilocaine 3% | 61
Ellingsson and Aasved, 1979 | To compare the effectiveness of etidocaine 1% versus lidocaine 2% using retrobulbar anesthesia. | 1 | 46 | Lidocaine 2% | 93 | 4
Ellingsson and Aasved, 1979 | To compare the effectiveness of etidocaine 1% versus lidocaine 2% using retrobulbar anesthesia. | 2 | 22 | Etidocaine 1% | 23 | 41
Ellingsson and Aasved, 1979 | To compare the effectiveness of etidocaine 1% versus lidocaine 2% using retrobulbar anesthesia. | 3 | 24 | Etidocaine 1% | 67 | 21
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 1 | 50 | Bupivacaine 0.75% | 52
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 2 | 50 | Ropivacaine 1% | 32
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 1 | 51 | Bupivacaine 0.5% | 39 | 61
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 2 | 50 | Bupivacaine 0.75% | 54 | 46
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 3 | 50 | Lidocaine 2% Bupivacaine 0.5% | 54 | 46
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 1 | 40 | Etidocaine 1.5% | 80 | 20
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 2 | 40 | Etidocaine 1% | 78 | 23
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 3 | 40 | Bupivacaine 0.75% | 80 | 20
Sarvela, 1993 | To compare the effectiveness of pH-adjusted 0.75% and 0.5% bupivacaine and 1% and 1.5% etidocaine | 4 | 40 | Bupivacaine 0.5% | 38 | 63
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 1 | 39 | Bupivacaine 0.75% | 64
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 2 | 43 | Lidocaine 2% Bupivacaine 0.75% | 95
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 1 | 15 | Mepivicaine 1% | 100
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 2 | 14 | Etidocaine 0.5% | 100
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 3 | 16 | Etidocaine 1% | 94
Vettese and Breslin, 1985 | To compare the effectiveness of three different retrobulbar anesthetic block preparations. | 1 | 15 | Bupivacaine 0.5% | 40 | 27
Vettese and Breslin, 1985 | To compare the effectiveness of three different retrobulbar anesthetic block preparations. | 2 | 15 | Lidocaine 2% Bupivacaine 0.5% | 40 | 33
Vettese and Breslin, 1985 | To compare the effectiveness of three different retrobulbar anesthetic block preparations. | 3 | 15 | Bupivacaine 0.5% Lidocaine 2% | 80 | 0

Evidence Table 12. Local anesthesia: Is there evidence that the volume of anesthetic used and speed of injection affect the amount of akinesia obtained and pain during the block or surgery with local blocks?

Author(s)/year | Study aim | Group | # subjects | Location Agent(s) used concentration (%) | Injection speed | % complete akinesia | % no pain during block | % no pain during surgery | Comments on akinesia
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 1 | 35 | Superomedial Inferotemporal Lidocaine 2% Bupivacaine 0.5% | Slow | 40 | 46
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 2 | 35 | Inferotemporal Superomedial Bupivacaine 0.5% Lidocaine 2% | Fast | 60 | 46
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 3 | 35 | Inferotemporal Superomedial Bupivacaine 0.5% Lidocaine 2% | Slow | 54 | 51
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 4 | 35 | Inferotemporal Superomedial Bupivacaine 0.5% Lidocaine 2% | Fast | 83 | 40
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 1 | 30 | Superomedial Inferotemporal Bupivacaine 0.75% | | | | | Maximum score for each quadrant = 2. Also measured lid function for total score of 10. Any score >= 3 was a failure.
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 2 | 30 | Superomedial Inferotemporal Bupivacaine 0.75% | | | | | 14 failures.
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 3 | 30 | Superomedial Inferotemporal Bupivacaine 0.75% | | | | | 15 failures.
Ortiz, Blanco, Serra et al., 1995 | To assess akinesia and intraocular pressure with peribulbar anesthesia with different volumes of bupivacaine with and without hyaluronidase. | 4 | 30 | Superomedial Inferotemporal Bupivacaine 0.75% | | | | | 12 failures.

Evidence Table 13. Local anesthesia: Is there evidence that the retrobulbar block technique is more or less painful than the peribulbar block during administration of the block?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean score (0-10) | Median score (0-10)
Murdoch, 1990 | To compare the effectiveness of two different bupivacaine hydrochloride products | 1 | 51 | Retrobulbar Subconjunctival | None | | | | 5.8
Murdoch, 1990 | To compare the effectiveness of two different bupivacaine hydrochloride products | 2 | 48 | Peribulbar | None | | | | 4.8
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 1 | 42 | Retrobulbar | Oral | | | | 3.8 | 3.5
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 2 | 43 | Peribulbar | Oral | | | | 3.3 | 3
Weiss and Deichman, 1989 | To compare the safety and effectiveness of retrobulbar and periocular anesthesia. | 1 | 40 | Retrobulbar | None | | | | 2.2
Weiss and Deichman, 1989 | To compare the safety and effectiveness of retrobulbar and periocular anesthesia. | 2 | 39 | Peribulbar | None | | | | 1.8
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 1 | 50 | Retrobulbar | None | 42 | 58 | 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 2 | 50 | Peribulbar | None | 36 | 64 | 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 3 | 50 | Retrobulbar | None | 60 | 40 | 0

Evidence Table 14. Local anesthesia: Is there evidence that retrobulbar block techniques are more painful for the patient while being administered than subconjunctival/sub-Tenon's block techniques?

Author(s)/year | Study aim | Group | # subjects | Block type | sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median Pain score (0-10) | Comments
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of sub-Tenon's and retrobulbar anesthesia. | 1 | 270 | Retrobulbar | None | 0 | 100 | 0 | 2.3 | 2
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of sub-Tenon's and retrobulbar anesthesia. | 2 | 300 | Subconjunctival/sub-Tenon's | None | 0 | 100 | 0 | 1.83 | 1
Khoo, Lim and Yong, 1996 | To compare the effectiveness of sub-Tenon's with retrobulbar anesthesia. | 1 | 55 | Subconjunctival/sub-Tenon's | None | 62 | 38
Khoo, Lim and Yong, 1996 | To compare the effectiveness of sub-Tenon's with retrobulbar anesthesia. | 2 | 51 | Retrobulbar | None | 2 | 76 | 13
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 1 | 43 | Retrobulbar | None | | | | 0.87 | | 56% of patients expressed a preference. 16% of patients would not have sub-Tenon's again, 19% would not have topical again, 40% would not have retrobulbar again.
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 2 | 44 | Subconjunctival/sub-Tenon's | None | | | | 0.15

Evidence Table 15. Local anesthesia: Is there evidence that peribulbar block techniques are more painful for the patient while being administered than subconjunctival/sub-Tenon's block techniques?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10) | Comments
Briggs, Beck, and Esakowitz, 1997 | To compare the effectiveness of sub-Tenon's and peribulbar anesthesia. | 1 | 76 | Peribulbar | None | 22 | 64 | 11 | 2.4 | 2
Briggs, Beck, and Esakowitz, 1997 | To compare the effectiveness of sub-Tenon's and peribulbar anesthesia. | 2 | 55 | Subconjunctival/sub-Tenon's | None | 55 | 40 | 4 | 1.4 | 0
Kollarits, Jaweed, and Kollarits, 1998 | To compare the effectiveness of peribulbar and sub-Tenon's anesthesia. | 1 | 100 | Peribulbar | None | 91 | 9
Kollarits, Jaweed, and Kollarits, 1998 | To compare the effectiveness of peribulbar and sub-Tenon's anesthesia. | 2 | 100 | Subconjunctival/sub-Tenon's | None | 99 | 1

Evidence Table 16. Local anesthesia: Summary of evidence regarding pain during administration of peribulbar block

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10) | Comments
Bell and Butt, 1995 | To test whether warming lidocaine reduces the pain of anesthetic injection for a peribulbar technique. | 1 | 30 | Peribulbar | None | 3 | 97 | 0 | 2.3 | 2
Bell and Butt, 1995 | To test whether warming lidocaine reduces the pain of anesthetic injection for a peribulbar technique. | 2 | 30 | Peribulbar | None | 0 | 50 | 50 | 5.5 | 6
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 1 | 27 | Peribulbar | None | 85
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 2 | 27 | Peribulbar | None | 26
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 1 | 40 | Peribulbar | Oral | | | | 2.52 | | 5.3% of patients stated they would prefer a more potent anxiolytic. 15% of patients stated they would prefer everything done the same way if another operation were required.
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 2 | 40 | Peribulbar | Oral | | | | 2.05
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 3 | 40 | Peribulbar | Oral | | | | 1.95
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 4 | 40 | Peribulbar | Oral | | | | 2.05
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 5 | 40 | Peribulbar | Oral | | | | 2.35
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 6 | 40 | Peribulbar | Oral | | | | 1.95
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 1 | 46 | Peribulbar | None | 63
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 2 | 44 | Peribulbar | None | 61
Gillart, Bazan, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 1 | 35 | Peribulbar | IV | 46 | 54 | 0
Gillart, Bazan, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 2 | 35 | Peribulbar | IV | 46 | 49 | 6
Gillart, Bazan, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 3 | 35 | Peribulbar | IV | 51 | 46 | 3
Gillart, Bazan, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 4 | 35 | Peribulbar | IV | 40 | 54 | 6
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 1 | 41 | Peribulbar | None | | | | 0.88
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 2 | 34 | Peribulbar | None | | | | 1.03
Herrick, Gelb, Nichols et al., 1996 | To assess the effectiveness of patient-controlled sedation with propofol. | 1 | 28 | Peribulbar | PCS | | | | | | Satisfaction was higher among the patients who received propofol PCS than in those who did not receive PCS. There was no difference between groups in regard to willingness to undergo a repeat procedure using the same technique.
Herrick, Gelb, Nichols et al., 1996 | To assess the effectiveness of patient-controlled sedation with propofol. | 2 | 27 | Peribulbar | None
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 1 | 50 | Peribulbar | None | | | | 2.3
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 2 | 50 | Peribulbar | None | | | | 2.2
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 1 | 40 | Peribulbar | Other | | | | | 18
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 2 | 40 | Peribulbar | Other | | | | | 16
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 3 | 40 | Peribulbar | Other | | | | | 14
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 4 | 40 | Peribulbar | Other | | | | | 17
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 1 | 39 | Peribulbar | None | | | | 2.8
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 2 | 43 | Peribulbar | None | | | | 2.6
Sweeney, Barber, and Prosser, 1993 | To compare a transcutaneous and transconjunctival method of periocular anesthesia. | 1 | 50 | Peribulbar | None | 18 | 54 | 28 | 3.9
Sweeney, Barber, and Prosser, 1993 | To compare a transcutaneous and transconjunctival method of periocular anesthesia. | 2 | 50 | Peribulbar | None | 42 | 58 | 0 | 1.2
Ursell and Spalton, 1996 | To assess the pain associated with peribulbar injection using room-temperature and warmed anesthetic agents. | 1 | 20 | Peribulbar | None | | | | 3.6
Ursell and Spalton, 1996 | To assess the pain associated with peribulbar injection using room-temperature and warmed anesthetic agents. | 2 | 20 | Peribulbar | None | | | | 5.3
Virkkila, Ali-Melkkila, and Kanto, 1992 | To compare IM alfentanil with IM midazolam for sedation. | 1 | 30 | Peribulbar | IM | | | | 35
Virkkila, Ali-Melkkila, and Kanto, 1992 | To compare IM alfentanil with IM midazolam for sedation. | 2 | 30 | Peribulbar | IM | | | | 44.7
Virkkila, Ali-Melkkila, and Kanto, 1992 | To compare IM alfentanil with IM midazolam for sedation. | 3 | 30 | Peribulbar | IM | | | | 53.7
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 1 | 30 | Peribulbar | IV | | | | | 1
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 2 | 30 | Peribulbar | IV | | | | | 1
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 3 | 30 | Peribulbar | IV | | | | | 1
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 4 | 30 | Peribulbar | IV | | | | | 1

Evidence Table 17. Local anesthesia: Summary of evidence regarding pain during administration of retrobulbar block

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10) | Comments
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 1 | 40 | Retrobulbar | Oral | | | | 2.52 | | About 5% of patients stated they would prefer a more potent anxiolytic, and almost 95% of patients stated they would prefer everything done the same way if another operation were required.
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 2 | 40 | Retrobulbar | Oral | | | | 2.05
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 3 | 40 | Retrobulbar | Oral | | | | 1.95
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 4 | 40 | Retrobulbar | Oral | | | | 2.05
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 5 | 40 | Retrobulbar | Oral | | | | 2.35
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 6 | 40 | Retrobulbar | Oral | | | | 1.95
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 1 | 71 | Retrobulbar | None | 41 | | 13
Hinshaw, Fiscella, and Sugar, 1995 | To compare pH-adjusted retrobulbar block with nonadjusted block. | 1 | 10 | Retrobulbar | None | | | | 6
Hinshaw, Fiscella, and Sugar, 1995 | To compare pH-adjusted retrobulbar block with nonadjusted block. | 2 | 11 | Retrobulbar | None | | | | 8.23
Joyce, Sunderraj, Villada et al., 1994 | To compare the pain of retrobulbar anesthesia with amethocaine cream, EMLA, and placebo. | 1 | 55 | Retrobulbar | None | 11 | 80 | 9 | 2.54 | 2
Joyce, Sunderraj, Villada et al., 1994 | To compare the pain of retrobulbar anesthesia with amethocaine cream, EMLA, and placebo. | 2 | 58 | Retrobulbar | None | 7 | 84 | 9 | 2.47 | 2
Joyce, Sunderraj, Villada et al., 1994 | To compare the pain of retrobulbar anesthesia with amethocaine cream, EMLA, and placebo. | 3 | 56 | Retrobulbar | None | 7 | 64 | 29 | 3.78 | 4
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 1 | 35 | Retrobulbar | None | | | | 4.5
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 2 | 35 | Retrobulbar | None | | | | 5.2
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 2 | 10 | Retrobulbar | Oral | | | 10 | 2.75
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 3 | 7 | Retrobulbar | Oral | | | | 0
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 4 | 7 | Retrobulbar | Oral | | | 14
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 1 | 40 | Retrobulbar | Other | | | | | 18
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 2 | 40 | Retrobulbar | Other | | | | | 16
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 3 | 40 | Retrobulbar | Other | | | | | 14
Sarvela, Nikki, and Paloheimo, 1993 | To assess the effectiveness of hyaluronidase and epinephrine in a peribulbar block. | 4 | 40 | Retrobulbar | Other | | | | | 17
Sunderraj, Kirby, Joyce et al., 1991 | To assess the effectiveness of EMLA in reducing the pain of retrobulbar injection. | 1 | 63 | Retrobulbar | None | 84 | 84 | 11 | 2.6
Sunderraj, Kirby, Joyce et al., 1991 | To assess the effectiveness of EMLA in reducing the pain of retrobulbar injection. | 2 | 52 | Retrobulbar | None | 121 | 65 | 29 | 3.8

Evidence Table 18. Local anesthesia: Summary of evidence regarding pain during administration of subconjunctival/sub-Tenon's block

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain
Guise, 1996 | To assess the effectiveness of sub-Tenon's block. | 1 | 300 | Subconjunctival | None | 68 | 31 | 1

Evidence Table 19. Local anesthesia: Is there evidence that retrobulbar block is more or less painful for the patient during administration than topical block?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Meanpain score (0-10) | Median pain score (0-10) | Comments
Patel, Burns, Crandall et al., 1996 | To compare the effectiveness of topical anesthesia to retrobulbar anesthesia. | 1 | 69 | Topical | IV | 41 | 58 | 0 | 1 | 1 | 13 patients had one eye done under each technique. Of these 13 patients, 8 preferred topical and 5 preferred retrobulbar.
Patel, Burns, Crandall et al., 1996 | To compare the effectiveness of topical anesthesia to retrobulbar anesthesia. | 2 | 69 | Retrobulbar | IV | 96 | 4 | 0 | 0 | 0
Patel, Clinch, Burns et al., 1998 | To assess the effectiveness of retrobulbar and topical anesthesia. | 1 | 45 | Topical | IV | 62 | 38 | | 0.78 | 0
Patel, Clinch, Burns et al., 1998 | To assess the effectiveness of retrobulbar and topical anesthesia. | 2 | 45 | Retrobulbar | IV | 82 | 18 | | 0.33 | 0

Evidence Table 20. Local anesthesia: Is there evidence that peribulbar block is more or less painful for the patient while being administered than topical block?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Meanpain score (0-10) | Median pain score (0-10) | Comments
Johnston, Whitefield, Giralt et al., 1998 | To compare topical and peribulbar anesthesia for clear corneal surgery. | 1 | 52 | Topical | None | | | | 1
Johnston, Whitefield, Giralt et al., 1998 | To compare topical and peribulbar anesthesia for clear corneal surgery. | 2 | 30 | Peribulbar | None | | | | 2.45
Roman, Auclin, and Ullern, 1996 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | 1 | 45 | Peribulbar | IV | 78 | 22 | 0 | 0 | 0.0
Roman, Auclin, and Ullern, 1996 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | 2 | 45 | Topical | IV | 100 | 0 | 0 | 0 | 0.0
Uusitalo, Maunuksela, Paloheimo et al., 1999 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | 1 | 136 | Topical | IV | | | | 0.9
Uusitalo, Maunuksela, Paloheimo et al., 1999 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | 2 | 163 | Peribulbar | IV | | | | 0.7
Virtanen and Huha, 1998 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | 1 | 51 | Peribulbar | None | 4 | 94 | 0 | 2.11 | 1.0
Virtanen and Huha, 1998 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | 1 | 51 | Topical | None | 4 | 94 | 0 | 2.11 | 1.0
Virtanen and Huha, 1998 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | 2 | 49 | Topical | None | 92 | 8 | 0 | 0.1 | 0.0

Evidence Table 21. Local anesthesia: Is there evidence the subconjunctival/sub-Tenon's block is more or less painful to the patient during administration than topical block?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 2 | 65 | Subconjunctival/sub-Tenon's | None | 85 | | 2
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 3 | 94 | Subconjunctival/sub-Tenon's | None | 99 | | 0
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 4 | 18 | Topical | None | 100 | | 0
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 5 | 100 | Topical | None | 100 | | 0

Evidence Table 22. Local anesthesia: Is there evidence that retrobulbar block techniques result in more or less pain during cataract surgery than peribulbar block techniques?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10)
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 1 | 51 | Retrobulbar | None | | | | 2.6
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 2 | 48 | Peribulbar | None | | | | 1.9
Sanders, Ahmed, Craig et al., 1997 | To compare the catecholamine and pressor effects in peribulbar and retrobulbar anesthesia. | 1 | 20 | Peribulbar | None | 90 | 10 | 0 | 0.2 | 0
Sanders, Ahmed, Craig et al., 1997 | To compare the catecholamine and pressor effects in peribulbar and retrobulbar anesthesia. | 2 | 20 | Retrobulbar | None | 90 | 10 | 0 | 0.1 | 0
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 1 | 42 | Retrobulbar | Oral | | | | 0.1
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 2 | 43 | Peribulbar | Oral | | | | 0 | 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 1 | 50 | Retrobulbar | None | 90 | 10 | 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 2 | 50 | Peribulbar | None | 92 | 8 | 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 3 | 50 | Retrobulbar | None | 100 | 0 | 0

Evidence Table 23. Local anesthesia: Is there evidence that retrobulbar block techniques result in more or less pain during cataract surgery than subconjunctival/sub-Tenon's block techniques?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10) | Comments
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of sub-Tenon's and retrobulbar anesthesia. | 1 | 270 | Retrobulbar | None | 0 | 94 | 6 | 2.74 | 2
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of sub-Tenon's and retrobulbar anesthesia. | 2 | 300 | Subconjunctival/sub-Tenon's | None | 0 | 100 | 0 | 1.55 | 1
Khoo, Lim, and Yong, 1996 | To compare the effectiveness of sub-Tenon's with retrobulbar anesthesia. | 1 | 55 | Subconjunctival/sub-Tenon's | None | 67 | 33 | 0
Khoo, Lim, and Yong, 1996 | To compare the effectiveness of sub-Tenon's with retrobulbar anesthesia. | 2 | 51 | Retrobulbar | None | 16 | 61 | 24
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with three local anesthesia techniques. | 1 | 43 | Retrobulbar | None | 79 | 21 | 0 | | | 56% of patients expressed a preference. 16% of patients would not have sub-Tenon's again, 19% would not have topical again, 40% would not have retrobulbar again.
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with three local anesthesia techniques. | 2 | 44 | Subconjunctival/sub-Tenon's | None | 64 | 36 | 0

Evidence Table 24. Local anesthesia: Is there evidence that peribulbar block techniques result in more or less pain during cataract surgery than subconjunctival/sub-Tenon's block techiques?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % severe pain | Median pain score (0-10)
Kollarits, Jaweed, and Kollarits, 1998 | To compare the effectiveness of peribulbar and sub-Tenon's anesthesia. | 1 | 100 | Peribulbar | None | 76 | 17 | 2
Kollarits, Jaweed, and Kollarits, 1998 | To compare the effectiveness of peribulbar and sub-Tenon's anesthesia. | 2 | 100 | Subconjunctival/sub-Tenon's | None | 79 | 14 | 3

Evidence Table 25. Local anesthesia: Summary of the evidence regarding pain during cataract surgery after peribulbar block

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10) | Comments
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 1 | 40 | Peribulbar | Oral | | | | 0.2 | | About 5% of patients stated they would prefer a more potent anxiolytic. Almost 95% of patients stated they would prefer everything done the same way if another operation were required.
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 2 | 40 | Peribulbar | Oral | | | | 0.45
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 3 | 40 | Peribulbar | Oral | | | | 0.15
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 4 | 40 | Peribulbar | Oral | | | | 0.15
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 5 | 40 | Peribulbar | Oral | | | | 0.65
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 6 | 40 | Peribulbar | Oral | | | | 0.2
Demirok, Simsek, Cinal et al., 1997 | To compare the effectiveness of one versus two injections of peribulbar anesthesia. | 1 | 57 | Peribulbar | None | | | | 0.74
Demirok, Simsek, Cinal et al., 1997 | To compare the effectiveness of one versus two injections of peribulbar anesthesia. | 2 | 63 | Peribulbar | None | | | | 0.6
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 1 | 46 | Peribulbar | None | 93
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 2 | 44 | Peribulbar | None | 98
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 1 | 41 | Peribulbar | None | | | | 1.17
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 2 | 34 | Peribulbar | None | | | | 0.91
Herrick, Gelb, Nichols et al., 1996 | To assess the effectiveness of patient-controlled sedation with propofol. | 1 | 28 | Peribulbar | PCS | | | | | | Satisfaction was higher among the patients who received propofol PCS than in those who did not receive PCS. There was no difference between groups in regard to willingness to undergo a repeat procedure using the same technique.
Herrick, Gelb, Nichols et al., 1996 | To assess the effectiveness of patient-controlled sedation with propofol. | 2 | 27 | Peribulbar | None
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 1 | 28 | Peribulbar | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 2 | 15 | Peribulbar | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 3 | 15 | Peribulbar | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 4 | 13 | Peribulbar | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 5 | 16 | Peribulbar | None | 88
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 6 | 15 | Peribulbar | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 7 | 15 | Peribulbar | None | 100
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 1 | 50 | Peribulbar | None | 88
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 2 | 50 | Peribulbar | None | 88
Johnston, Whitefield, Giralt et al., 1998 | To compare topical and peribulbar anesthesia for clear corneal surgery. | 2 | 30 | Peribulbar | None | | | | | 0
Kollarits, Jaweed, and Kollarits, 1998 | To compare the effectiveness of peribulbar and sub-Tenon's anesthesia. | 1 | 100 | Peribulbar | None | 76 | 17 | 2
Kothari, Shah, Shah et al., 1998 | To evaluate the effectiveness of peribulbar injection supplemented by topical anesthesia. | 1 | 500 | Peribulbar | IV | 74 | 26 | 0
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 1 | 51 | Peribulbar | None | 100
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 2 | 50 | Peribulbar | None | 100
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 3 | 50 | Peribulbar | None | 100
Muller, Claasen, Schall et al., 1996 | To compare the effectiveness of two different bupivacaine hydrochloride products. | 1 | 52 | Peribulbar | None | 88
Muller, Claasen, Schall et al., 1996 | To compare the effectiveness of two different bupivacaine hydrochloride products. | 2 | 48 | Peribulbar | None | 88
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 2 | 48 | Peribulbar | None | | | | 1.9
Roman, Auclin, and Ullern, 1996 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | 1 | 45 | Peribulbar | IV | 96 | 4
Sanders, Ahmed, Craig et al., 1997 | To compare the catecholamine and pressor effects in peribulbar and retrobulbar anesthesia. | 1 | 20 | Peribulbar | None | 90 | 10 | 0 | 0.2 | 0
Sarvela and Nikki, 1992b | To compare the effectiveness of a 31 mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 1 | 48 | Peribulbar | IV | 83
Sarvela and Nikki, 1992b | To compare the effectiveness of a 31 mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 2 | 49 | Peribulbar | IV | 94
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 2 | 43 | Peribulbar | Oral | | | | 0 | 0
Uusitalo, Maunuksela, Paloheimo et al., 1999 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | 2 | 163 | Peribulbar | IV | 93 | 7 | 0 | 0.1
Virtanen and Huha, 1998 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | 1 | 51 | Peribulbar | None | 76 | 24 | 0 | 0.85 | 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 2 | 50 | Peribulbar | None | 92 | 8 | 0
Zehetmayer, Radax, Skorpik et al., 1996 | To compare patient pain and satisfaction with topical anesthesia in one eye and peribulbar anesthesia in the other. | 2 | 36 | Peribulbar | Oral | | | | 1.1

Evidence Table 26. Local anesthesia: Summary of the evidence regarding pain during cataract surgery after retrobulbar block

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Meanpain score (0-10) | Median pain score (0-10) | Comments
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 1 | 40 | Retrobulbar | Oral | | | | 0.2 | | About 5% of patients stated they would prefer a more potent anxiolytic. Almost 95% of patients stated they would prefer everything done the same way if another operation were required.
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 2 | 40 | Retrobulbar | Oral | | | | 0.45
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 3 | 40 | Retrobulbar | Oral | | | | 0.15
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 4 | 40 | Retrobulbar | Oral | | | | 0.15
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 5 | 40 | Retrobulbar | Oral | | | | 0.65
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 6 | 40 | Retrobulbar | Oral | | | | 0.2
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 1 | 71 | Retrobulbar | None | 83 | | 0
Gutman, Sinskey, and Cain, 1979 | To compare the effectiveness of lidocaine compared to etidocaine for retrobulbar anesthesia. | 1 | 27 | Retrobulbar | IV | 93 | 7
Gutman, Sinskey, and Cain, 1979 | To compare the effectiveness of lidocaine compared to etidocaine for retrobulbar anesthesia. | 2 | 25 | Retrobulbar | IV | 100 | 0 | 0
Ibrahim and Savino, 1974 | To compare effectiveness of intravenous valium with a combination of meperidine, phenobarbital, and promethazine for sedation. | 1 | 32 | Retrobulbar | IV | 63
Ibrahim and Savino, 1974 | To compare effectiveness of intravenous valium with a combination of meperidine, phenobarbital, and promethazine for sedation. | 2 | 35 | Retrobulbar | IV | 63
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 1 | 35 | Retrobulbar | None | 0 | 74 | 26 | 4.5 | 5
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 2 | 35 | Retrobulbar | None | 0 | 69 | 31 | 5.2 | 5

Evidence Table 27. Local anesthesia: Summary of the evidence regarding pain during cataract surgery after subconjunctival/sub-Tenson's injection

Author(s)/year | Study aim | Group | # subjects | Sedation | % no pain | % mild/moderate pain | % severe pain | Meanpain score (0-10) | Median pain score (0-10)
Anderson, 1995 | To report the results of a subconjunctival anesthesia technique. | 1 | 133 | IV | 90
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 2 | 65 | None | 85 | | 2
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 3 | 94 | None | 99 | | 0
Manners and Burton, 1996 | To compare the effectiveness of topical versus sub-Tenon's local anesthesia. | 2 | 25 | None | | | | 0.02
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 2 | 44 | None | 64 | 36 | 0

Evidence Table 28. Local anesthesia: Is there evidence that retrobulbar block techniques result in more or less pain during cataract surgery than topical block?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/moderate pain | % severe pain | Meanpain score (0-10) | Median pain score (0-10)
Jolliffe, Abdel-Khalek, and Norton, 1997 | To compare the effectiveness of topical anesthesia with Van Lint block and retrobulbar block. | 1 | 19 | Topical | Oral | 32 | 47 | 21
Jolliffe, Abdel-Khalek, and Norton, 1997 | To compare the effectiveness of topical anesthesia with Van Lint block and retrobulbar block. | 2 | 21 | Retrobulbar | Oral | 48 | 48 | 5
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 1 | 43 | Retrobulbar | None | 79 | 21 | 0
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 2 | 44 | Subconjunctival | None | 64 | 36 | 0
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 3 | 43 | Topical | None | 44 | 56 | 0
Patel, Burns, Crandall et al., 1996 | To compare the effectiveness of topical anesthesia to retrobulbar anesthesia. | 1 | 69 | Topical | IV | 83 | 17 | | 0.0 | 1.1
Patel, Burns, Crandall et al., 1996 | To compare the effectiveness of topical anesthesia to retrobulbar anesthesia. | 2 | 69 | Retrobulbar | IV | 91 | 9 | | 0.0 | 0.2
Patel, Clinch, Burns et al., 1998 | To assess the effectiveness of retrobulbar and topical anesthesia. | 1 | 45 | Topical | IV | 69 | 31 | 0 | 0.8 | 0.0
Patel, Clinch, Burns et al., 1998 | To assess the effectiveness of retrobulbar and topical anesthesia. | 2 | 45 | Retrobulbar | IV | 89 | 11 | 0 | 0.2 | 0.0

Evidence Table 29. Local anesthesia: Is there evidence that peribulbar block techniques result in more or less pain during cataract surgery than topical block techniques?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/ moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10)
Johnston, Whitefield, Giralt et al., 1998 | To compare topical and peribulbar anesthesia for clear corneal surgery. | 1 | 52 | Topical | None | | | | | 2
Johnston, Whitefield, Giralt et al., 1998 | To compare topical and peribulbar anesthesia for clear corneal surgery. | 2 | 30 | Peribulbar | None | | | | | 0
Roman, Auclin, and Ullern, 1996 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | 1 | 45 | Peribulbar | IV | 96 | 4
Roman, Auclin, and Ullern, 1996 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | 2 | 45 | Topical | IV | 93 | 7
Uusitalo, Maunuksela, Paloheimo et al., 1999 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | 1 | 136 | Topical | IV | 70 | 26 | 4 | 0.8
Uusitalo, Maunuksela, Paloheimo et al., 1999 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | 2 | 163 | Peribulbar | IV | 93 | 7 | 0 | 0.1
Virtanen and Huha, 1998 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | 1 | 51 | Peribulbar | None | 76 | 24 | 0 | 0.85 | 0
Virtanen and Huha, 1998 | To compare the effectiveness of topical anesthesia and peribulbar anesthesia using a scleral incision. | 2 | 49 | Topical | None | 12 | 86 | 2 | 2.76 | 1
Zehetmayer, Radax, Skorpik et al., 1996 | To compare patient pain and satisfaction with topical anesthesia in one eye and peribulbar anesthesia in the other. | 1 | 36 | Topical | Oral | | | | 1.1
Zehetmayer, Radax, Skorpik et al., 1996 | To compare patient pain and satisfaction with topical anesthesia in one eye and peribulbar anesthesia in the other. | 2 | 36 | Peribulbar | Oral | | | | 1.1

Evidence Table 30. Local anesthesia: Is there evidence that subconjunctival/sub-Tenon's block techniques result in more or less pain during cataract surgery than topical block techniques?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/ moderate pain | % severe pain | Mean pain score (0-10) | Comments
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 1 | 71 | Retrobulbar | None | 83 | | 0
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 2 | 65 | Subconjunctival/ sub-Tenon's | None | 85 | | 2
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 3 | 94 | Subconjunctival/ sub-Tenon's | None | 99 | | 0
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 4 | 18 | Topical | None | 78 | | 0
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 5 | 100 | Topical | None | 69 | | 0
Manners and Burton, 1996 | To compare the effectiveness of topical versus sub-Tenon's local anesthesia. | 1 | 25 | Topical | None | | | | 0.46
Manners and Burton, 1996 | To compare the effectiveness of topical versus sub-Tenon's local anesthesia. | 2 | 25 | Subconjunctival/ sub-Tenon's | None | | | | 0.02
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 1 | 43 | Retrobulbar | None | 79 | 21 | 0 | | 56% of patients expressed a preference. 16% of patients would not have sub-Tenon's again, 19% would not have topical again, 40% would not have retrobulbar again.
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 2 | 44 | Subconjunctival/sub-Tenon's | None | 64 | 36 | 0 | | 56% of patients expressed a preference. 16% of patients would not have sub-Tenon's again, 19% would not have topical again, 40% would not have retrobulbar again.
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 3 | 43 | Topical | None | 44 | 56 | 0 | | 56% of patients expressed a preference. 16% of patients would not have sub-Tenon's again, 19% would not have topical again, 40% would not have retrobulbar again.

Evidence Table 31. Local anesthesia: Is pain control improved by adding intracameral Iidocaine to topical anesthesia?

Author(s)/year | Study aim | Group | # subjects | Block type | Sedation | % no pain | % mild/ moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10)
Anderson, Nath, and Anderson, 1999 | To compare the effectiveness of intracameral bupivacaine versus intracameral lidocaine for topical anesthesia. | 1 | 24 | Topical Intracameral Lidocaine | IV | 88 | 13
Anderson, Nath, and Anderson, 1999 | To compare the effectiveness of intracameral bupivacaine versus intracameral lidocaine for topical anesthesia. | 2 | 24 | Topical Intracameral Lidocaine | IV | 88 | 13
Carino, Slomovic, Chung et al., 1998 | To compare the effectiveness of topical tetracaine to topical tetracaine plus intracameral lidocaine. | 1 | 30 | Topical | None | 47 | 53 | 0 | 0.6 | 1
Carino, Slomovic, Chung et al., 1998 | To compare the effectiveness of topical tetracaine to topical tetracaine plus intracameral lidocaine. | 2 | 30 | Topical Intracameral Lidocaine | None | 77 | 23 | 0 | 0.21 | 0
Crandall, Zabriskie, Patel et al., 1999 | To compare the effectiveness of topical anesthesia with and without intracameral lidocaine. | 1 | 68 | Topical Intracameral Lidocaine | None | 69 | 29 | 1 | 0.86 | 0
Crandall, Zabriskie, Patel et al., 1999 | To compare the effectiveness of topical anesthesia with and without intracameral lidocaine. | 2 | 68 | Topical | None | 56 | 28 | 1 | 1.2 | 0
Dinsmore, 1995 | To report an approach to topical anesthesia. | 1 | 136 | Topical | None | 95
Gills, Cherchio, and Raanan, 1997 | To assess the effect of unpreserved lidocaine on pain under topical anesthesia. | 1 | 183 | Topical Intracameral Lidocaine | None | 90 | 9
Gills, Cherchio, and Raanan, 1997 | To assess the effect of unpreserved lidocaine on pain under topical anesthesia. | 2 | 120 | Topical | None | 74 | 26
Kershner, 1993 | To evaluate the effectiveness of topical anesthesia. | 1 | 100 | Topical | None | 100 | 0 | 0
Tseng and Chen, 1998 | To compare the effectiveness of topical lidocaine alone to topical lidocaine with intracameral lidocaine. | 1 | 81 | Topical | Oral | 49 | 68 | 0 | 0.6
Tseng and Chen, 1998 | To compare the effectiveness of topical lidocaine alone to topical lidocaine with intracameral lidocaine. | 2 | 81 | Topical Intracameral Lidocaine | Oral | 51 | 32 | 0 | 0.4
Zehetmayer, Rainer, Turnheim et al., 1997 | To compare the use of pH-adjusted lidocaine 4% to plain lidocaine 4% for clear corneal surgery. | 1 | 17 | Topical | Oral | | | | 0.973
Zehetmayer, Rainer, Turnheim et al., 1997 | To compare the use of pH-adjusted lidocaine 4% to plain lidocaine 4% for clear corneal surgery. | 2 | 17 | Topical | Oral | | | | 0.1

Evidence Table 32. Local anesthesia: Is there evidence that using hyaluronidase reduces the amount of pain experienced by the patient during cataract surgery?

Author(s)/year | Study aim | Group | # subjects | Hyaluronidase | Sedation | % no pain | % mild/moderate pain | % severe pain
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 1 | 28 | Yes | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 2 | 15 | Yes | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 3 | 15 | No | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 4 | 13 | Yes | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 5 | 16 | No | None | 88
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 6 | 15 | No | None | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 7 | 15 | Yes | None | 100

Evidence Table 33. Local anesthesia: Is there evidence that certain anesthetic agents result in more or less pain during cataract surgery than other agents?

Author(s)/year | Study aim | Group | # subjects | Agent(s) | Sedation | % no pain | % mild/moderate pain | % severe pain | Mean pain score (0-10) | Median pain score (0-10) | Comments
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lignocaine. | 1 | 46 | Lidocaine Bupivacaine | None | 93
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lignocaine. | 2 | 44 | Prilocaine | None | 98
Gutman, Sinskey, and Cain, 1979 | To compare the effectiveness of lidocaine and etidocaine for retrobulbar anesthesia. | 1 | 27 | Lidocaine | IV | 93 | 7
Gutman, Sinskey, and Cain, 1979 | To compare the effectiveness of lidocaine and etidocaine for retrobulbar anesthesia. | 2 | 25 | Etidocaine | IV | 100 | 0 | 0
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lignocaine 1% and bupivacaine 0.5%. | 1 | 41 | Prilocaine | None | | | | 1.17
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lignocaine 1% and bupivacaine 0.5%. | 2 | 34 | Bupivacaine Lidocaine | None | | | | 0.91
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 1 | 28 | Lidocaine Bupivacaine | Oral | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 2 | 15 | Bupivacaine | Oral | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 3 | 15 | Bupivacaine Lidocaine | Oral | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 4 | 13 | Bupivacaine | Oral | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 5 | 16 | Bupivacaine | Oral | 88
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 6 | 15 | Bupivacaine | Oral | 100
House, Hollands, and Schulzer, 1991 | To assess the effectiveness of different combinations of lidocaine, bupivacaine, epinephrine, and hyaluronidase for peribulbar anesthesia. | 7 | 15 | Lidocaine Bupivacaine | Oral | 100
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 1 | 50 | Bupivacaine | None | 88
Huha, Ala-Kokko, Salomaki et al., 1999 | To compare the effectiveness and pharmacokinetics of 1% ropivacaine with 0.75% bupivacaine. | 2 | 50 | Ropivicaine | None | 88
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 1 | 51 | Bupivacaine | None | 100
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 2 | 50 | Bupivacaine | None | 100
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 3 | 50 | Bupivacaine Lidocaine | None | 100
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 1 | 39 | Bupivacaine | None | | | | | | No difference in pain reports.
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 2 | 43 | Lidocaine Bupivacaine | None

Evidence Table 34. Local anesthesia: Is there evidence that warming of the anesthetic agents results in improved akinesia or pain control during the block and during the operation?

Author(s)/year | Study aim | Group | # subjects | Agent(s) | Surgical time and technique | % complete akinesia | % no pain during block | % no pain during surgery | % mean pain during block
Bell and Butt, 1995 | To test whether warming lidocaine reduces the pain of anesthetic injection for a peribulbar technique. | 1 | 30 | Lidocaine | ECCE | | 3
Bell and Butt, 1995 | To test whether warming lidocaine reduces the pain of anesthetic injection for a peribulbar technique. | 2 | 30 | Lidocaine | ECCE | | 0
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 1 | 35 | Lidocaine | | 77 | | 0
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 2 | 35 | Lidocaine | | 60 | | 0
Ursell and Spalton, 1996 | To assess the pain associated with peribulbar injection using room-temperature and warmed anesthetic agents. | 1 | 20 | Lidocaine | PE | | | | 3.6
Ursell and Spalton, 1996 | To assess the pain associated with peribulbar injection using room-temperature and warmed anesthetic agents. | 2 | 20 | Lidocaine | PE | | | | 5.3

Evidence Table 35. Local anesthesia: Is there evidence that pH adjustment yields more effective local blocks?

Author(s)/year | Study aim | Group | # subjects | Agent(s) | pH buffering? | Surgical technique | % no akinesia | % complete akinesia | Mean pain during block (0-10) | Mean pain during surgery (0-10)
Hinshaw, Fiscella, and Sugar, 1995 | To compare pH-adjusted retrobulbar block with nonadjusted block. | 1 | 10 | Bupivacaine Lidocaine | Yes | Can't tell | | | 6.0
Hinshaw, Fiscella, and Sugar, 1995 | To compare pH-adjusted retrobulbar block with nonadjusted block. | 2 | 11 | Bupivacaine Lidocaine | No | Can't tell | | | 8.2
Lewis, Hamilton, Brant et al., 1992 | To assess the effectiveness of pH adjustment of bupivacaine in peribulbar block. | 1 | 26 | Bupivacaine | No | Can't tell | 35
Lewis, Hamilton, Brant et al., 1992 | To assess the effectiveness of pH adjustment of bupivacaine in peribulbar block. | 2 | 24 | Bupivacaine | Yes | Can't tell | 25
Zehetmayer, Rainer, Turnheim et al., 1997 | To assess the effectiveness of pH adjustment of a solution of lidocaine and bupivacaine in reducing pain on injection. | 1 | 17 | Lidocaine Bupivacaine | Yes | PE clear cornea | | | | .98
Zehetmayer, Rainer, Turnheim et al., 1997 | To assess the effectiveness of pH adjustment of a solution of lidocaine and bupivacaine in reducing pain on injection. | 2 | 17 | Lidocaine Bupivacaine | No | PE clear cornea | | | | 1.0

Evidence Table 36. Local anesthesia: Summary of the evidence regarding complications of retrobulbar blocks

Author(s)/year | Study aim | Group | # subjects | Location of injections | Agent(s) | Surgical technique | % with ocular complications | % with systemic complications | Adverse comments | HEMO comments
Ali-Melkkila, Virkkila, Leino et al., 1993 | To compare the effectiveness of two methods of peribulbar anesthesia with retrobulbar anesthesia. | 1 | 150 | Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0
Athanikar and Agrawal, 1991 | To compare the effectiveness of peribulbar anesthesia to retrobulbar anesthesia. | 1 | 71 | Inferotemporal | Lidocaine | ECCE | RH: 1
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam, in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 1 | 40 | Inferotemporal | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam, in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 2 | 40 | Inferotemporal | Bupivacaine Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam, in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 3 | 40 | Inferotemporal | Bupivacaine Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam, in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 4 | 40 | Inferotemporal | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam, in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 5 | 40 | Inferotemporal | Bupivacaine Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam, in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 6 | 40 | Inferotemporal | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Buttery and Wise, 1989 | To compare the effectiveness of retrobulbar anesthesia using transdermal and a transconjunctival technique. | 1 | 23 | Can't tell | Lidocaine | Can't tell | RH: 13
Buttery and Wise, 1989 | To compare the effectiveness of retrobulbar anesthesia using transdermal and a transconjunctival technique. | 2 | 25 | Transconjunctival | Lidocaine | Can't tell | RH: 4
Corboy and Jiang, 1997 | To assess the cause of postoperative hypotropia after cataract surgery. | 1 | 2,143 | Can't tell | Bupivacaine | PE | STR: 1
Edge, McClarty, Krige et al., 1995 | To compare retrobulbar to peribulbar anesthesia. | 1 | 209 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0
Feibel, Custer, and Gordon, 1993 | To assess the rates of ptosis using retrobulbar or two-injection peribulbar anesthesia. | 2 | 163 | Can't tell | Mepivicaine Bupivacaine | ECCE | PTO: 6
Gilbert, Holt, Johnston et al., 1987 | To compare the effectiveness of nalbuphine and methohexital versus fentanyl and diazepam. | 1 | 28 | Can't tell | Lidocaine Bupivacaine | Can't tell | | HTN: 0 TACH: 0 BRADY: 0 | | There were no significant differences between groups, regarding hemodynamics.
Gilbert, Holt, Johnston et al., 1987 | To compare the effectiveness of nalbuphine and methohexital versus fentanyl and diazepam. | 2 | 27 | Can't tell | Lidocaine Bupivacaine | Can't tell | | HTN: 0 TACH: 0 BRADY: 0
Hamilton, Gimbel, and Strunin, 1988 | To assess the safety and effectiveness of 12,000 regional anesthetics administered by one doctor using 5 different techniques of injection anesthesia. | 1 | 3,595 | Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0 Other: optic atrophy | NSARR: 1 | Vasovagal
Hosal, Tekeli, and Gursel 1998 | To estimate the rate of and risk factors for eye lid malpositions following cataract surgery. | 1 | 124 | Can't tell | Lidocaine | ECCE | PTO: 7
Jolliffe, Abdel-Khalek, and Norton, 1997 | To compare the effectiveness of topical anesthesia with Van Lint block and retrobulbar block. | 2 | 21 | Can't tell | Bupivacaine Lidocaine | Can't tell | PCR: 14 Expulsive hemorrhage: 5 | | | No significant differences in heart rate distributions during surgery.
Joyce, Sunderraj, Villada et al., 1994 | To compare the pain of retrobulbar anesthesia with amethocaine cream, EMLA, and placebo. | 1 | 55 | Superotemporal Inferotemporal | Bupivacaine | Can't tell | Local reaction to topical: 0
Joyce, Sunderraj, Villada et al., 1994 | To compare the pain of retrobulbar anesthesia with amethocaine cream, EMLA, and placebo. | 2 | 58 | Inferotemporal Superotemporal | Bupivacaine | Can't tell | Local reaction to topical: 0
Joyce, Sunderraj, Villada et al., 1994 | To compare the pain of retrobulbar anesthesia with amethocaine cream, EMLA, and placebo. | 3 | 56 | Inferotemporal Superotemporal | Bupivacaine | Can't tell | Local reaction to topical: 0
Kaplan, Jaffe, and Clayman, 1985 | To compare different facial blocks and bridle sutures for their effect on postoperative ptosis. | 1 | 55 | Inferotemporal | | PE | PTO: 60
Kaplan, Jaffe, and Clayman, 1985 | To compare different facial blocks and bridle sutures for their effect on postoperative ptosis. | 2 | 51 | Inferotemporal | | PE | PTO: 45
Kaplan, Jaffe, and Clayman, 1985 | To compare different facial blocks and bridle sutures for their effect on postoperative ptosis. | 3 | 41 | Inferotemporal | | PE | PTO: 59
Kaplan, Jaffe, and Clayman, 1985 | To compare different facial blocks and bridle sutures for their effect on postoperative ptosis. | 4 | 47 | Inferotemporal | | PE | PTO: 36
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of sub-Tenon's and retrobulbar anesthesia. | 1 | 270 | Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 2 RG: 0 BSA: 0
Khalil, Howard, Mankarious et al., 1998 | To compare alfentanil to lidocaine IV for reducing patient response to retrobulbar block. | 1 | 20 | Can't tell | Bupivacaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 5 SPO2: 0 | | Alfentanil significantly attenuates hemodynamic responses to block placement versus lidocaine (IV) or placebo.
Khalil, Howard, Mankarious et al., 1998 | To compare alfentanil to lidocaine IV for reducing patient response to retrobulbar block. | 2 | 20 | Can't tell | Bupivacaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 0
Khalil, Howard, Mankarious et al., 1998 | To compare alfentanil to lidocaine IV for reducing patient response to retrobulbar block. | 3 | 20 | Can't tell | Bupivacaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 0
Khoo, Lim, and Yong, 1996 | To compare the effectiveness of sub-Tenon's with retrobulbar anesthesia. | 2 | 51 | Inferotemporal | Lidocaine | | RH: 0 RG: 0 BSA: 0
Kost and Emerson, 1992 | To compare propofol and fentanyl versus midazolam and fentanyl for sedation. | 1 | 37 | Can't tell | Lidocaine Bupivacaine | Can't tell | | | | The propofol/ fentanyl group had significantly less desaturation with no differences in hemodynamics.
Kost and Emerson, 1992 | To compare propofol and fentanyl versus midazolam and fentanyl for sedation. | 2 | 37 | Can't tell | Lidocaine Bupivacaine | Can't tell
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 1 | 35 | Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Krause, Weindler, and Ruprecht, 1997 | To compare the effectiveness of warmed anesthetic to room-temperature anesthetic using a retrobulbar injection. | 2 | 35 | Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Krohn, Seland Hovding et al., 1993 | To assess the benefit of hyaluronidase in retrobulbar anesthesia. | 1 | 40 | Transconjunctival | Lidocaine | ECCE | RH: 0 RG: 0 BSA: 0 PCR: 0
Krohn, Seland Hovding et al., 1993 | To assess the benefit of hyaluronidase in retrobulbar anesthesia. | 2 | 40 | Transconjunctival | Lidocaine | ECCE | RH: 0 RG: 0 BSA: 0 PCR: 8
Michelson and Naujoks, 1991 | To compare respiratory function with and without supplemental 02 administration during cataract surgery. | 1 | 21 | Can't tell | Mepivicaine | Can't tell | | SPO2: 52
Michelson and Naujoks, 1991 | To compare respiratory function with and without supplemental 02 administration during cataract surgery. | 2 | 10 | Can't tell | Mepivicaine | Can't tell | | SPO2: 0 | | Oxygen saturation (3L/min nasal cannual, Group B) was higher in the group with oxygen supplemen-tation.
Mjahed, el Harrar, Hamdani et al., 1996 | To compare the effectiveness of retrobulbar block using lidocaine versus lidocaine and clonidine. | 1 | 30 | Can't tell | Lidocaine | Can't tell | | BRADY: 0 | | Clonidine group had a decrease in heart rate and blood pressure compared to baseline.
Mjahed, el Harrar, Hamdani et al., 1996 | To compare the effectiveness of retrobulbar block using lidocaine versus lidocaine and clonidine. | 2 | 30 | Can't tell | Lidocaine | Can't tell | | BRADY: 7
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 1 | 51 | Inferotemporal | Bupivacaine Lidocaine | ECCE | RH: 2 RG: 0 BSA: 0 PCR: 6 | Other: 6
Nielsen, 1995 | To compare visual acuities after retrobulbar and topical anesthesia. | 1 | 25 | Can't tell | Lidocaine Bupivacaine | PE clear cornea | RH: 12 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 76 Diplopia: 52 | | 32
Oikkonen, 1994 | To compare oral melperon with oral diazepam for sedation. | 1 | 50 | Can't tell | Bupivacaine Lidocaine | Can't tell | | BRADY: 2
Oikkonen, 1994 | To compare oral melperon with oral diazepam for sedation. | 2 | 50 | Can't tell | Bupivacaine Lidocaine | Can't tell | | BRADY: 0 | | One patient in group 2 had significant hypotension.
Oikkonen, Heine, Salminen et al., 1994 | To compare oral dixyrazine with oral diazepam for sedation. | 1 | 50 | Can't tell | Lidocaine Bupivacaine | ECCE | | | | Five Group 2 patients had significant hypotension, compared to only 1 in diazepam group (melperon). One patient was treated for bradycardia. The patient's group was not reported.
Oikkonen, Heine, Salminen et al., 1994 | To compare oral dixyrazine with oral diazepam for sedation. | 2 | 50 | Can't tell | Lidocaine Bupivacaine | ECCE
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen in saturation during cataract surgery. | 1 | 9 | Can't tell | Bupivacaine Lidocaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 SPO2: 0 | | Higher heart rates in Group 1.
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 2 | 10 | Can't tell | Lidocaine Bupivacaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 SPO2: 0
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 3 | 7 | Can't tell | Bupivacaine Lidocaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 SPO2: 0
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 4 | 7 | Can't tell | Lidocaine Bupivacaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 SPO2: 0
Patel, Burns, Crandall et al., 1996 | To compare the effectiveness of topical anesthesia to retrobulbar anesthesia. | 2 | 69 | Can't tell | Lidocaine Bupivacaine | PE clear cornea | RH: 1 RG: 0 BSA: 0 PCR: 1 STR: 0 PTO: 0
Patel, Clinch, Burns et al., 1998 | To assess the effectiveness of retrobulbar and topical anesthesia. | 2 | 45 | Can't tell | Lidocaine Bupivacaine | PE clear cornea | RH: 2 PCR: 2
Sanchez-Capuchino, Meadows, and Morgan, 1993 | To compare the effectiveness of retrobulbar anesthesia with and without facial block. | 1 | 25 | Can't tell | Prilocaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Sanchez-Capuchino, Meadows, and Morgan, 1993 | To compare the effectiveness of retrobulbar anesthesia with and without facial block. | 2 | 25 | Can't tell | Prilocaine | Can't tell | RH: 4 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Sanders, Ahmed, Craig et al., 1997 | To compare the catecholamine and pressor effects in peribulbar and retrobulbar anesthesia. | 2 | 20 | Can't tell | Lidocaine | ECCE | | | | Was reported as mean MAP and mean HR, not as number of patients above limits or treatment for abnormalities. There was no significant difference between HR and MAP in the peribulbar versus retrobulbar groups.
Saunders, Sturgess, Pemberton. et al., 1993 | To compare the effectiveness of peribulbar and retrobulbar administration of prilocaine. | 1 | 42 | Inferomedial | Bupivacaine | Can't tell | RH: 2 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Shammas, Milkie, and Yeo, 1997 | To compare the effectiveness of topical anesthesia with a small injection of subconjunctival anesthesia to retrobulbar anesthesia. | 1 | 205 | Inferotemporal | Lidocaine | PE | RH: 1 RG: 0 BSA: 0 PCR: 4
Smith and Kim, 1980 | To compare the effectiveness of lidocaine with etidocaine for retrobulbar block. | 1 | 25 | Can't tell | Lidocaine | Can't tell | | | | No significant change in mean heart rates. Mean systolic and diastolic BP showed gradual decrease during postoperative period in both treatment groups.
Smith and Kim, 1980 | To compare the effectiveness of lidocaine with etidocaine for retrobulbar block. | 2 | 25 | Can't tell | Etidocaine | Can't tell
Smith and Smith, 1983 | To compare the effectiveness of lidocaine with epinephrine to etidocaine with and without epinephrine for retrobulbar block. | 1 | 21 | Can't tell | Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 | | No difference in heart rate or blood pressure before, during, or after surgery.
Smith and Smith, 1983 | To compare the effectiveness of lidocaine with epinephrine to etidocaine with and without epinephrine for retrobulbar block. | 2 | 20 | Can't tell | Etidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Smith and Smith, 1983 | To compare the effectiveness of lidocaine with epinephrine to etidocaine with and without epinephrine for retrobulbar block. | 3 | 21 | Can't tell | Etidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Sunderraj, Kirby, Joyce et al., 1991 | To assess the effectiveness of EMLA in reducing the pain of retrobulbar injection. | 1 | 63 | Inferotemporal | Bupivacaine | Can't tell | Local side effects: 0
Sunderraj, Kirby, Joyce et al., 1991 | To assess the effectiveness of EMLA in reducing the pain of retrobulbar injection. | 2 | 52 | Inferotemporal | Bupivacaine | Can't tell | Local side effects: 0
Thomson, 1988 | To assess the effectiveness of adding hyaluronidase to lidocaine in retrobulbar block. | 1 | 75 | Inferotemporal Inferomedial | Lidocaine | ICCE | PCR: 3
Thomson, 1988 | To assess the effectiveness of adding hyaluronidase to lidocaine in retrobulbar block. | 2 | 75 | Inferotemporal Inferomedial | Lidocaine | ICCE | PCR: 7
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 1 | 15 | Inferotemporal | Mepivicaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0
Thorburn, Thorn-Alquist, and Edstrom, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 2 | 14 | Inferotemporal | Etidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0
Weiss and Deichman, 1989 | To compare the safety and effectiveness of retrobulbar and periocular anesthesia. | 1 | 40 | Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HR>100: 3 | Other, unspecified tachy-cardia: one for Group 1 and none for Group 2. | One patient in Group 1 had tachycardia, but not stated whether it required treatment.
Whitsett, Balyeat, and McClure, 1990 | To compare peribulbar and retrobulbar anesthesia. | 2 | 50 | Can't tell | Bupivacaine Lidocaine | ECCE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 1 | 50 | Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 3 | 50 | Superomedial | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Yee, Burns, Mann et al., 1996 | To compare propofol alone to combinations of propofol and alfentanil for sedation and patient comfort and adverse outcomes. | 1 | 10 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 20 | | There was no significant difference between Groups, A, B, or C. There was a significant decrease in MAP and SP02 in Group D versus Groups A, B, and C.
Yee, Burns, Mann et al., 1996 | To compare propofol alone to combinations of propofol and alfentanil for sedation and patient comfort and adverse outcomes. | 2 | 10 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 10
Yee, Burns, Mann et al., 1996 | To compare propofol alone to combinations of propofol and alfentanil for sedation and patient comfort and adverse outcomes. | 3 | 10 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 0
Yee, Burns, Mann et al., 1996 | To compare propofol alone to combinations of propofol and alfentanil for sedation and patient comfort and adverse outcomes. | 4 | 10 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 40

Evidence Table 37. Local anesthesia: Summary of the evidence regarding complications of peribulbar blocks

Author(s)/year | Study aim | Group | # subjects | Location of injections | Agent(s) | Surgical technique | % with ocular complications | % with systemic complications | HEMO Comments
Agrawal and Athanikar, 1994 | To report the effectiveness of a single-injection, low-volume, periocular anesthesia. | 1 | 1,000 | Inferotemporal Superotemporal | Lidocaine | ECCE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 Chemosis: 13
Ali-Melkkila, Virkkila, Leino et al., 1993 | To compare the effectiveness of two methods of peribulbar anesthesia with retrobulbar anesthesia. | 2 | 150 | Inferotemporal Superomedial | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Ali-Melkkila, Virkkila, Leino et al., 1993 | To compare the effectiveness of two methods of peribulbar anesthesia with retrobulbar anesthesia. | 3 | 150 | Inferomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Athanikar and Agrawal, 1991 | To compare the effectiveness of peribulbar anesthesia to retrobulbar anesthesia. | 2 | 71 | Inferotemporal | Lidocaine | ECCE | RH: 0
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 1 | 27 | Inferomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Bjornstrom, Hansen, Otland et al., 1994 | To assess the benefit of adrenalin and hyaluronidase in peribulbar injection effectiveness. | 2 | 27 | Inferotemporal Inferomedial | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 1 | 40 | Inferotemporal Superomedial | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 2 | 40 | Inferotemporal Superomedial | Bupivacaine Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 3 | 40 | Superomedial Inferotemporal | Bupivacaine Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 4 | 40 | Inferotemporal Superomedial | Bupivacaine Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 5 | 40 | Superomedial Inferotemporal | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Boezaart, Berry, Laubscher et al., 1998 | To compare the effectiveness of bromazepam, alprazolam, and diazepam in different doses for anxiolysis and comfort during combined peribulbar and retrobulbar block. | 6 | 40 | Inferotemporal Superomedial | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Briggs, Beck, Esakowitz et al., 1997 | To compare the effectiveness of sub-Tenon's and peribulbar anesthesia. | 1 | 76 | Can't tell | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Davis and Mandel, 1986 | To compare posterior peribulbar anesthesia to retrobulbar anesthesia. | 1 | 1,600 | Inferomedial Superomedial | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 1 | 54 | Superotemporal Superomedial Inferomedial | Lidocaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 2 | 46 | Superotemporal Superomedial Inferomedial | Lidocaine Bupivacaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Demirok, Simsek, Cinal et al., 1997 | To compare the effectiveness of one versus two injections of peribulbar anesthesia. | 1 | 57 | Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0
Demirok, Simsek, Cinal et al., 1997 | To compare the effectiveness of one versus two injections of peribulbar anesthesia. | 2 | 63 | Superomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 1 | 46 | Inferomedial | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Dopfmer, Maloney, Gaynor et al., 1996 | To compare akinesia achieved with prilocaine versus bupivacaine plus lidocaine. | 2 | 44 | Inferomedial | Prilocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Edge, McClarty, Krige et al., 1995 | To compare retrobulbar to peribulbar anesthesia. | 2 | 199 | Superomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 | Other: severe headache
Feibel, Custer, and Gordon, 1993 | To assess the rates of ptosis using retrobulbar or two-injection peribulbar anesthesia. | 1 | 154 | Inferotemporal Superomedial | Mepivicaine Bupivacaine | ECCE | PTO: 6
Gillart, Bazin, Deret et al., 1996 | To assess the effect of the pressure on injection of local anesthesia during peribulbar block. | 1 | 25 | Superomedial Inferotemporal Superotemporal | Bupivacaine Etidocaine | Can't tell | | | 7% decrease in mean arterial pressure in both groups.
Gillart, Bazin, Deret et al., 1996 | To assess the effect of the pressure on injection of local anesthesia during peribulbar block. | 2 | 25 | Inferotemporal Superomedial Superotemporal | Bupivacaine Etidocaine | Can't tell | | | 7% decrease in mean arterial pressure in both groups.
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 1 | 35 | Superomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 2 | 35 | Inferotemporal Superomedial | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 3 | 35 | Superomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0
Gillart, Bazin, Montetagaud et al., 1998 | To assess the effect of volume and speed of administration with local anesthesia or peribulbar block. | 4 | 35 | Superomedial Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 1 | 41 | Transconjunctival Inferotemporal Inferomedial | Prilocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 5
Henderson and Franks, 1996 | To compare the effectiveness of prilocaine 2% and a combination of lidocaine 1% and bupivacaine 0.5%. | 2 | 34 | Transconjunctival Inferomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0
Hendrick, Rosenberg, and Lebenbom-Mansour, 1997 | To report the effectiveness and safety of peribulbar block performed by anesthesiologists. | 1 | 1,074 | Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Herrick, Gelb, Nichols et al., 1996 | To assess the effectiveness of patient-controlled sedation with propofol. | 1 | 28 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 4 | There was no statistically significant difference in hemodynamics between groups.
Herrick, Gelb, Nichols et al., 1996 | To assess the effectiveness of patient-controlled sedation with propofol. | 2 | 27 | Can't tell | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 0
Khurana, Sachdeva, Gombar et al., 1994 | To compare the effectiveness of peribulbar with subconjunctival anesthesia. | 1 | 100 | Superomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Kothari, Shah, Shah et al., 1998 | To evaluate the effectiveness of peribulbar injection supplemented by topical anesthesia. | 1 | 500 | Inferotemporal | Lidocaine | PE clear cornea | PCR: 1
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 1 | 51 | Can't tell | Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 2 | 50 | Can't tell | Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Loots, Koorts, and Venter, 1993 | To compare the effectiveness of bupivacaine in 2 doses and bupivacaine and lidocaine in a combination for peribulbar anesthesia. | 3 | 50 | Can't tell | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 2 | 48 | Inferotemporal Superomedial | Lidocaine Bupivacaine | ECCE | RH: 0 RG: 0 BSA: 0 PCR: 2 Other: vitreous loss
Nathan, Benrhaiem, Lotfi et al., 1996 | To compare the pharmacokinetics of lidocaine and bupivacaine with and without hyaluronidase for peribulbar anesthesia. | 1 | 10 | Superomedial Inferomedial | Bupivacaine Lidocaine | Can't tell | RH: 10
Nathan, Benrhaiem, Lotfi et al., 1996 | To compare the pharmacokinetics of lidocaine and bupivacaine with and without hyaluronidase for peribulbar anesthesia. | 2 | 10 | Superomedial Inferomedial | Lidocaine Bupivacaine | Can't tell
Oikkonen, 1994 | To compare oral melperon with oral diazepam for sedation. | 1 | 50 | Can't tell | Bupivacaine Lidocaine | Can't tell | | BRADY: 2
Oikkonen, 1994 | To compare oral melperon with oral diazepam for sedation. | 2 | 50 | Can't tell | Lidocaine Bupivacaine | Can't tell | | BRADY: 0 | One patient with significant hypotension.
Oikkonen, Heine, Salminen et al., 1994 | To compare oral dixyrazine with oral diazepam for sedation. | 1 | 50 | Can't tell | Lidocaine Bupivacaine | ECCE | | | Five dixyrazine patients had significant hypotension, compared to only 1 in diazepam group. One patient was treated for bradycardia. The patient's group was not reported.
Oikkonen, Heine, Salminen et al., 1994 | To compare oral dixyrazine with oral diazepam for sedation. | 2 | 50 | Can't tell | Lidocaine Bupivacaine | ECCE
Pac-Soo, Deacock, Lockwood et al., 1996 | To compare self-administered midazolam or propofol with saline for sedation and hemodynamic effect. | 1 | 26 | Can't tell | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 4 STR: 0 PTO: 0 | HTN: 4 TACH: 0 BRADY: 0 SPO2: 0 | No clinically significant changes in HR in any of the groups. HR exceeded 90 beats/min in 33% of patients. There were significant increases in the systolic BP in the saline and propofol groups.
Pac-Soo, Deacock, Lockwood et al., 1996 | To compare self-administered midazolam or propofol with saline for sedation and hemodynamic effect. | 2 | 24 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | HTN: 0 TACH: 0 BRADY: 0 SPO2: 4
Pac-Soo, Deacock, Lockwood et al., 1996 | To compare self-administered midazolam or propofol with saline for sedation and hemodynamic effect. | 3 | 25 | Can't tell | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | HTN: 0 SPO2: 0
Roman, Auclin, and Ullern, 1996 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | 1 | 45 | Inferotemporal Superotemporal | Bupivacaine Lidocaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 0 PTO: 0 Other: eye bruise
Sanders, Ahmed, Craig et al., 1997 | To compare the catecholamine and pressure effects in peribulbar and retrobulbar anesthesia. | 1 | 20 | Inferotemporal Superomedial | Lidocaine | ECCE | | | Reported as mean MAP and mean HR. Number of patients treated not reported. No significant difference between HR and MAP in the peribulbar versus retrobulbar groups.
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 1 | 35 | Inferotemporal | Etidocaine | Can't tell | Other: subconjunctival hematoma
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 2 | 35 | Inferotemporal | Etidocaine | Can't tell | Other: subconjunctival hematoma
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 3 | 40 | Inferomedial Inferotemporal Trans-conjunctival | Etidocaine | Can't tell | Other: subconjunctival hematoma
Sarvela and Nikki, 1992a | To assess the effect of hyaluronidase in peribulbar anesthesia. | 4 | 40 | Inferomedial Inferotemporal Trans-conjunctival | Etidocaine | Can't tell | Other: subconjunctival hematoma
Sarvela and Nikki, 1992b | To compare the effectiveness of a 31 mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 1 | 48 | Inferotemporal | Etidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Sarvela and Nikki, 1992b | To compare the effectiveness of a 31 mm needle versus a 22 mm needle for retrobulbar block with etidocaine. | 2 | 49 | Inferomedial Inferotemporal | Etidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 1 | 39 | Inferotemporal Transconjunctival | Bupivacaine | PE | RH: 0 RG: 0 BSA: 0
Sarvela, Paloheimo, and Nikki, 1994 | To compare pH-adjusted bupivacaine 0.75% with a mixture of bupivacaine 0.75% and lidocaine 2%. | 2 | 43 | Inferotemporal Transconjunctival | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0
Saunders, Sturgess, Pemberton et al., 1993 | To compare the effectiveness of peribulbar versus retrobulbar administration of prilocaine. | 2 | 43 | Inferotemporal Superomedial | Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 2 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Thorburn, Thorn-Alquist, and Edstorm, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 1 | 15 | Superomedial | Mepivicaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0
Thorburn, Thorn-Alquist, and Edstorm, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 2 | 14 | Superomedial | Etidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 0
Thorburn, Thorn-Alquist, and Edstorm, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 3 | 3,478 | Inferotemporal Superomedial | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0 | NSARR: 1 Vasovagal
Thorburn, Thorn-Alquist, and Edstorm, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 4 | 2,226 | Superomedial Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0 | NSARR: 0 Vasovagal
Thorburn, Thorn-Alquist, and Edstorm, 1976 | To compare the effectiveness of etidocaine with mepivicaine in retrobulbar anesthesia. | 5 | 1,061 | Superomedial Inferotemporal | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0 | NSARR: 1 Vasovagal
Uusitalo, Maunuksela, Paloheimo et al., 1999 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | 2 | 163 | Can't tell | Lidocaine Bupivacaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 3 Other: endophthalmitis
Virkkila, Ali-Melkkila, and Kanto, 1992 | To compare IM alfentanil with IM midazolam for sedation. | 1 | 30 | Can't tell | Bupivacaine Lidocaine | Can't tell | | HTN: 0 TACH: 0 BRADY: 3 SPO2: 0 | Significant increase in HR following regional block in all 3 groups. The smallest increase was in the alfentanil group.
Virkkila, Ali-Melkkila, and Kanto, 1992 | To compare IM alfentanil with IM midazolam for sedation. | 2 | 30 | Can't tell | Lidocaine Bupivacaine | Can't tell | | HTN: 0 TACH: 0 BRADY: 3 SPO2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | To compare IM alfentanil with IM midazolam for sedation. | 3 | 30 | Can't tell | Bupivacaine Lidocaine | Can't tell | | HTN: 0 TACH: 0 BRADY: 0 SPO2: 0
Virkkila, Ali-Melkkila, Kanto et al., 1993 | To assess the sedative and hemodynamic effects of different doses of IM dexmedetomi-dine. | 1 | 7 | Can't tell | Bupivacaine Lidocaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 | No significant differences in SPO2 between groups.
Virkkila, Ali-Melkkila, Kanto et al., 1993 | To assess the sedative and hemodynamic effects of different doses of IM dexmedetomi-dine. | 2 | 7 | Can't tell | Bupivacaine Lidocaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 0
Virkkila, Ali-Melkkila, Kanto et al., 1993 | To assess the sedative and hemodynamic effects of different doses of IM dexmedetomi-dine. | 3 | 7 | Can't tell | Bupivacaine Lidocaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 0
Virkkila, Ali-Melkkila, Kanto et al., 1993 | To assess the sedative and hemodynamic effects of different doses of IM dexmedetomi-dine. | 4 | 7 | Can't tell | Lidocaine Bupivacaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 14
Virkkila, Ali-Melkkila, Kanto et al., 1993 | To assess the sedative and hemodynamic effects of different doses of IM dexmedetomi-dine. | 5 | 7 | Can't tell | Bupivacaine Lidocaine | Can't tell | | HTN: 0 HR>100: 0 TACH: 0 BRADY: 0 | Significant decrease in HR and systolic BP only in Group E.
Virkkila, Ali-Melkkila, Kanto et al., 1994 | To assess the sedative and hemodynamic effects of dexmedetomidine and midazolam. | 1 | 30 | Can't tell | Lidocaine Bupivacaine | ECCE | RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 0 | Mean HR and BP, not number of patients per group, reported.
Virkkila, Ali-Melkkila, Kanto et al., 1994 | To assess the sedative and hemodynamic effects of dexmedetomidine and midazolam. | 2 | 30 | Can't tell | Bupivacaine Lidocaine | ECCE | RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HR>100: 0 TACH: 0 BRADY: 7 SPO2: 0
Virkkila, Ali-Melkkila, Kanto et al., 1994 | To assess the sedative and hemodynamic effects of dexmedetomidine and midazolam. | 3 | 30 | Can't tell | Lidocaine Bupivacaine | ECCE | RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HR>100: 0 TACH: 0 BRADY: 0 SPO2: 0
Weiss and Deichman, 1989 | To compare the safety and effectiveness of retrobulbar and periocular anesthesia. | 2 | 39 | Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HR>100: 0 | One patient in Group A had tachycardia, but not stated whether it required treatment.
Whitsett, Balyeat, and McClure, 1990 | To compare peribulbar and retrobulbar anesthesia. | 1 | 50 | Inferotemporal | Lidocaine Bupivacaine | ECCE | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Wong, Koehrer, Sutton et al., 1993 | To compare the effectiveness of a superomedial retrobulbar block with an inferolateral retrobulbar block and a peribulbar block. | 2 | 50 | Superomedial Inferotemporal | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0 STR: 0 PTO: 0 | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HR>100:
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 1 | 30 | Can't tell | Bupivacaine Lidocaine | Can't tell | | SPO2: 0 | Sedation was associated with lower heart rate and blood pressure.
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 2 | 30 | Can't tell | Lidocaine Bupivacaine | Can't tell | | SPO2: 0
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 3 | 30 | Can't tell | Lidocaine Bupivacaine | Can't tell | | SPO2: 23
Wong and Merrick, 1996 | To assess the effectiveness of midazolam, alfentanil, or both compared with a placebo on pain, recall, and hemodynamics. | 4 | 30 | Can't tell | Bupivacaine Lidocaine | Can't tell | | SPO2: 7
Zehetmayer, Radax, Skorpik et al., 1996 | To compare patient pain and satisfaction with topical anesthesia in one eye and peribulbar anesthesia in the other. | 2 | 36 | Inferotemporal | Lidocaine Bupivacaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 6 STR: 0 PTO: 0 Other: orbital hemorrhage

Evidence Table 38. Local anesthesia: Summary of the evidence on complication rates with subconjunctival anesthesia

Author(s)/year | Study aim | Group | # subjects | Agent(s) | Surgical technique | % with ocular complications | % with systemic complications | Adverse comments | Hemodynamics comments
Anderson, 1995 | To report the results of a subconjunctival anesthesia technique. | 1 | 133 | Lidocaine Bupivacaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 1
Briggs, Beck, and Esakowitz, 1997 | To compare the effectiveness of sub-Tenon's and peribulbar anesthesia. | 2 | 55 | Lidocaine Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Cugini, Lanzetta, Nadbath et al., 1997 | To assess the effectiveness of ketamine for sedation and pain control. | 1 | 40 | Mepivicaine | Can't tell | | | | 3 minutes after sedation, the control group showed a significant decrease in systolic BP as compared to the ketamine group. There were no significant differences between groups in regard to HR or diastolic BP.
Cugini, Lanzetta, Nadbath et al., 1997 | To assess the effectiveness of ketamine for sedation and pain control. | 2 | 40 | Mepivicaine | Can't tell
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 1 | 54 | Lidocaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Davis and O'Connor, 1989 | To compare the effectiveness of 2% lidocaine and 2% lidocaine plus 0.5% bupivacaine in peribulbar anesthesia. | 2 | 46 | Lidocaine Bupivacaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 2 | 65 | Lidocaine | PE | | | | Systolic blood pressure increased from 12 to 16 mmHg in each group (except not studied in the topical group)
Fukasaku and Marron, 1994 | To compare a topical with two subconjunctival regional anesthetic techniques. | 3 | 94 | Lidocaine | PE
Furuta, Toriumi, Kashiwagi et al., 1990 | To assess the effectiveness of a method of sub-Tenon's anesthesia. | 1 | 176 | Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0 PCR: 1
Guise, 1996 | To assess the effectiveness of sub-Tenon's block. | 1 | 300 | Bupivacaine | Can't tell | RH: 0 RG: 0 BSA: 0
Kapran, Uyar, Eltutar et al., 1996 | To compare the effectiveness of sub-Tenon's and retrobulbar anesthesia. | 2 | 300 | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0
Khoo, Lim, and Yong, 1996 | To compare the effectiveness of sub-Tenon's with retrobulbar anesthesia. | 1 | 55 | Lidocaine | | RH: 0 RG: 0 BSA: 0
Khurana, Sachdeva, Gombar et al., 1994 | To compare the effectiveness of peribulbar with subconjunctival anesthesia. | 2 | 100 | Bupivacaine Lidocaine | Can't tell | RH: 0 RG: 0 BSA: 0
Murdoch, 1990 | To compare the effectiveness of retrobulbar anesthesia to peribulbar anesthesia. | 1 | 51 | Bupivacaine Lidocaine | ECCE | RH: 2 RG: 0 BSA: 0 PCR: 6
Nielsen and Allerod, 1998 | To evaluate patient pain and preference with 3 local anesthesia techniques. | 2 | 44 | Lidocaine Bupivacaine | PE clear cornea | PCR: 2
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 1 | 9 | Bupivacaine Lidocaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 SPO2: 0 | | Higher heart rates in Group 1.
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 2 | 10 | Lidocaine Bupivacaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 SPO2: 0
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 3 | 7 | Lidocaine Bupivacaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 SPO2: 0
Oikkonen and Reinikainen, 1996 | To assess a possible relationship between silent myocardial ischemia and decreases in arterial oxygen saturation during cataract surgery. | 4 | 7 | Lidocaine Bupivacaine | Can't tell | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 SPO2: 0
Petersen and Yanoff, 1991 | To describe a technique of sub-Tenon's anesthesia. | 1 | 385 | Lidocaine | PE | RG: 0
Shammas, Milkie, and Yeo, 1997 | To compare the effectiveness of topical anesthesia with a small injection of subconjunctival anesthesia to retrobulbar anesthesia. | 1 | 205 | Lidocaine | PE | RH: 1 RG: 0 BSA: 0 PCR: 4
Shammas, Milkie, and Yeo, 1997 | To compare the effectiveness of topical anesthesia with a small injection of subconjunctival anesthesia to retrobulbar anesthesia. | 2 | 197 | Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 1

Evidence Table 39. Local anesthesia: Summary of the evidence on complication rates with topical anesthesia

Author(s)/year | Study aim | Group | # subjects | Agent(s) | Surgical technique | % with ocular complications | % with systemic complications | Adverse comments | HEMO comments
Crandall, Zabriskie, Patel et al., 1999 | To compare the effectiveness of topical anesthesia with and without intracameral lidocaine. | 1 | 68 | Bupivacaine Intracameral Lidocaine | PE clear cornea | PCR: 0 | | | 12 with elevated blood pressure during surgery.
Crandall, Zabriskie, Patel et al., 1999 | To compare the effectiveness of topical anesthesia with and without intracameral lidocaine. | 2 | 68 | Bupivacaine | PE clear cornea | PCR: 0 | | | 14 with elevated blood pressure during surgery.
Gills, Cherchio, and Raanan, 1997 | To assess the effect of unpreserved lidocaine on pain under topical anesthesia. | 1 | 183 | Proparacaine Bupivacaine Intracameral Lidocaine | PE | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0 | | There were no significant differences between groups regarding systolic or diastolic BP.
Gills, Cherchio, and Raanan, 1997 | To assess the effect of unpreserved lidocaine on pain under topical anesthesia. | 2 | 120 | Proparacaine Bupivacaine | PE | | MI: 0 CHF: 0 VARR: 0 NSARR: 0 Stroke: 0 TIA: 0 RF: 0 HOSP: 0 HTN: 0
Hodgkins, Teye-Botchway, Morrell et al., 1992 | To assess the effectiveness of a combination of intravenous sedation, facial nerve block, and topical anesthesia. | 1 | 1,817 | Amethocaine | ECCE | PCR: 2 | RF: 0
John, 1998 | To describe a technique combining topical and intracameral anesthesia. | 1 | 51 | Tetracaine Intracameral Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0
John, 1998 | To describe a technique combining topical and intracameral anesthesia. | 2 | 51 | Lidocaine | PE | RH: 0 RG: 0 BSA: 0 PCR: 0
Masket and Gokmen, 1998 | To study the effect of intracameral lidocaine on patient and surgeon comfort during small-incision surgery. | 1 | 352 | Tetracaine Lidocaine | PE clear cornea | Corneal edema: 23
Masket and Gokmen, 1998 | To study the effect of intracameral lidocaine on patient and surgeon comfort during small-incision surgery. | 2 | 279 | Tetracaine Lidocaine Intracameral Lidocaine | PE clear cornea | Corneal edema: 12
Nielsen, 1995 | To compare visual acuities after retrobulbar and topical anesthesia. | 2 | 31 | Lidocaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Patel, Burns, Crandall et al., 1996 | To compare the effectiveness of topical anesthesia to retrobulbar anesthesia. | 1 | 69 | Bupivacaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Patel, Clinch, Burns et al., 1998 | To assess the effectiveness of retrobulbar and topical anesthesia. | 1 | 45 | Bupivacaine | PE clear cornea | RH: 0 PCR: 0
Roman, Auclin, and Ullern, 1996 | To compare patient preferences and responses to topical anesthesia in one eye and peribulbar anesthesia in the other. | 2 | 45 | Tetracaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 2 PTO: 2
Tseng and Chen, 1998 | To compare the effectiveness of topical lidocaine alone to topical lidocaine with intracameral lidocaine. | 1 | 81 | Lidocaine Intracameral Placebo | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 0 STR: 0 PTO: 0
Tseng and Chen, 1998 | To compare the effectiveness of topical lidocaine alone to topical lidocaine with intracameral lidocaine. | 2 | 81 | Lidocaine Intracameral Lidocaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 1 STR: 0 PTO: 0
Uusitalo, Maunuksela, Paloheimo et al., 1999 | To compare the safety and effectiveness of topical with peribulbar anesthesia. | 1 | 136 | Bupivacaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 1
Zehetmayer, Radax, Skorpik et al., 1996 | To compare patient pain and satisfaction with topical anesthesia in one eye and peribulbar anesthesia in the other. | 1 | 36 | Lidocaine | PE clear cornea | RH: 0 RG: 0 BSA: 0 PCR: 6 STR: 0 PTO: 0
Zehetmayer, Rainer, Turnheim et al., 1997 | To compare the use of pH-adjusted lidocaine 4% to plain lidocaine 4% for clear corneal surgery. | 1 | 17 | Lidocaine Oxybuprocaine | PE clear cornea | Corneal staining: 12
Zehetmayer, Rainer, Turnheim et al., 1997 | To compare the use of pH-adjusted lidocaine 4% to plain lidocaine 4% for clear corneal surgery. | 2 | 17 | Lidocaine Oxybuprocaine | PE clear cornea | Corneal staining: 6

Evidence Table 40. Sedation: Is sedation associated with improved pain control/patient cooperation compared to local anesthesia alone?

Author(s)/year | Group | Planned sedation | Surgeon assessment of cooperation % | % with no pain during A: block B: surgery | % with mild/moderate pain during A: block B: surgery | % with severe pain during A: block B: surgery | Mean pain score A: block B: surgery | Median pain score A: block B: surgery
Pac-Soo, Deacock, Lockwood et al., 1996 | 1 | PCA Placebo | 25
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | PCA Benzodiazepines | 21
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | PCA Propofol | 24
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | IM Analgesics | | | | | A: 3.5
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | IM Benzodiazepines | | | | | A: 4.5
Virkkila, Ali-Melkkila, and Kanto, 1992 | 3 | IM Placebo | | | | | A: 5.4
Wong and Merrick, 1996 | 1 | IV Placebo | | | | | | A: 1.4
Wong and Merrick, 1996 | 2 | IV Benzodiazepines | | | | | | A: 1.2
Wong and Merrick, 1996 | 3 | IV Analgesics | | | | | | A: 0.9
Wong and Merrick, 1996 | 4 | IV Benzodiazepines Analgesics | | | | | | A: 0.6

Evidence Table 41. Sedation: Is sedation associated with improved anxiety control/patient satisfaction compared to local anesthesia alone?

Author(s)/year | Group | Planned sedation | Anxiety (% of patients reporting) | | | Patient satisfaction (% of patients reporting)
Author(s)/year | Group | Planned sedation | None | Mild/ moderate | Severe | Excellent | Very good | Good | Fair | Poor
Wong and Merrick, 1996 | 1 | IV Placebo | | | | 93 | | 7
Wong and Merrick, 1996 | 2 | IV Benzodiazepines | | | | 100
Wong and Merrick, 1996 | 3 | IV Analgesics | | | | 100
Wong and Merrick, 1996 | 4 | IV Benzodiazepines Analgesics | | | | 100

Evidence Table 42. Sedation: Is sedation associated with improved hemodynamics outcomes compared to local anesthesia alone?

Author(s)/year | Group | Planned sedation | Hemodynamics (% of patients experiencing)
Pac-Soo, Deacock, Lockwood et al., 1996 | 1 | PCA Placebo | Hypertension: 4 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | PCA Benzodiazepines | Hypertension: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 4:
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | PCA Propofol | Hypertension: 0 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | IM Analgesics | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | IM Benzodiazepines | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 3 | IM Placebo | Hypertension: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Wong and Merrick, 1996 | 1 | IV Placebo | Supplemental O2: 0
Wong and Merrick, 1996 | 2 | IV Benzodiazepines | Supplemental O2: 0
Wong and Merrick, 1996 | 3 | IV Analgesics | Supplemental O2: 23
Wong and Merrick, 1996 | 4 | IV Benzodiazepines Analgesics | Supplemental O2: 7

Evidence Table 43. Sedation: Summary of evidence on the effectiveness of oral and intramuscular sedation regarding patient cooperation and pain

Author(s)/year | Group | Planned sedation | Surgeon assessment of cooperation | % with no pain during A: block B: surgery | % with mild/moderate pain during A: block B: surgery | % with severe pain during A: block B: surgery | Mean pain score (0-10) A: block B: surgery | Median pain score (0-10) A: block B: surgery
Boezaart, Berry, Laubscher et al., 1998 | 1 | Oral | | | | | A: 2.52 B: 0.2
Boezaart, Berry, Laubscher et al., 1998 | 2 | Oral | | | | | A: 2.05 B: 0.45
Boezaart, Berry, Laubscher et al., 1998 | 3 | Oral | | | | | A: 1.95 B: 0.15
Boezaart, Berry, Laubscher et al., 1998 | 4 | Oral | | | | | A: 2.05 B: 0.15
Boezaart, Berry, Laubscher et al., 1998 | 5 | Oral | | | | | A: 2.35 B: 0.65
Boezaart, Berry, Laubscher et al., 1998 | 6 | Oral | | | | | A: 1.95 B: 0.2
Ellingsson and Aasved, 1979 | 1 | IM | 43
Ellingsson and Aasved, 1979 | 2 | IM | 5
Ellingsson and Aasved, 1979 | 3 | IM | 16
Jolliffe, Abdel-Khalek, and Norton, 1997 | 1 | Oral | | B: 32 | B: 47 | B: 21
Jolliffe, Abdel-Khalek, and Norton, 1997 | 2 | Oral | | B: 48 | B: 48 | B: 5
Oikkonen and Reinikainen, 1996 | 2 | Oral | | | | A: 10 | A: 2.75
Oikkonen and Reinikainen, 1996 | 3 | Oral | | | | | A: 0
Oikkonen and Reinikainen, 1996 | 4 | Oral | | | | A: 14
Pappa, Pouliou, Nastou et al., 1995 | 1 | IM | | | | A: 0 | A: 1.85
Pappa, Pouliou, Nastou et al., 1995 | 2 | IM | | | | A: 50 | A: 3
Sarvela, 1993 | 1 | Other | | | | | | A: 18
Sarvela, 1993 | 2 | Other | | | | | | A: 16
Sarvela, 1993 | 3 | Other | | | | | | A: 14
Sarvela, 1993 | 4 | Other | | | | | | A: 17
Saunders, Sturgess, Pemberton et al., 1993 | 1 | Oral | | | | | A: 3.8 B: 0.1 | A: 3.5 B: 0
Saunders, Sturgess, Pemberton et al., 1993 | 2 | Oral | | | | | A: 3.3 B: 0 | A: 3 B: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | IM | | | | | A: 3.5
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | IM | | | | | A: 4.5
Virkkila, Ali-Melkkila, and Kanto, 1992 | 3 | IM | | | | | A: 5.4
Zehetmayer, Radax, Skorpik et al., 1996 | 1 | Oral | | | | | B: 1.1
Zehetmayer, Radax, Skorpik et al., 1996 | 2 | Oral | | | | | B: 1.1
Zehetmayer, Rainer, Turnheim et al., 1997 | 1 | Oral | | | | | B: 0.973
Zehetmayer, Rainer, Turnheim et al., 1997 | 2 | Oral | | | | | B: 0.1

Evidence Table 44. Sedation: Summary of evidence on the effectiveness of oral and intramuscular sedation regarding anxiety and satisfaction

Author(s)/year | Group | Planned sedation | Anxiety (% of patients reporting) | | | Patient satisfaction (% of patients reporting) | | | | | % desiring management again
Author(s)/year | Group | Planned sedation | None | Mild/moderate | Severe | Excellent | Very good | Good | Fair | Poor | % desiring management again
Ali-Melkkila, Virkkila, Leino et al., 1993 | 1 | Oral | | | | | | | | | 98
Ali-Melkkila, Virkkila, Leino et al., 1993 | 2 | Oral | | | | | | | | | 100
Ali-Melkkila, Virkkila, Leino et al., 1993 | 3 | Oral | | | | | | | | | 99
Jolliffe, Abdel-Khalek, and Norton, 1997 | 1 | Oral | | | | | | | | | 84
Jolliffe, Abdel-Khalek, and Norton, 1997 | 2 | Oral | | | | | | | | | 90
Oikkonen, Heine, Salminen et al., 1994 | 1 | Oral | 24
Oikkonen, Heine, Salminen et al., 1994 | 2 | Oral | 16

Evidence Table 45. Sedation: Summary of evidence on the effectiveness of oral or intramuscular sedation regarding medical and hemodynamic complications

Author(s)/year | Group | Planned sedation | Medical outcomes (% of patients experiencing) | Hemodynamics (% of patients experiencing)
Oikkonen, Heine, Salminen et al., 1994 | 1 | Oral | | Bradycardia: 2
Oikkonen, Heine, Salminen et al., 1994 | 2 | Oral | | Bradycardia: 0
Oikkonen and Reinikainen, 1996 | 1 | Oral | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 | Supplemental O2:
Oikkonen and Reinikainen, 1996 | 2 | Oral | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 | Supplemental O2: 0
Oikkonen and Reinikainen, 1996 | 3 | Oral | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 | Supplemental O2: 0
Oikkonen and Reinikainen, 1996 | 4 | Oral | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 | Supplemental O2: 0
Sanchez-Capuchino, Meadows, and Morgan, 1993 | 1 | Oral | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0
Sanchez-Capuchino, Meadows, and Morgan, 1993 | 2 | Oral | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0
Saunders, Sturgess, Pemberton et al., 1993 | 1 | Oral | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0
Saunders, Sturgess, Pemberton et al., 1993 | 2 | Oral | MI: 0 CHF: 2 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | IM | | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | IM | | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 3 | IM | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1993 | 1 | IM | | Hypertension: 0 HR >100: 0 Tachycardia: 0 Bradycardia: 0
Virkkila, Ali-Melkkila, and Kanto, 1993 | 2 | IM | | Hypertension: 0 HR >100: 0 Tachycardia: 0 Bradycardia: 0
Virkkila, Ali-Melkkila, and Kanto, 1993 | 3 | IM | | Hypertension: 0 HR >100: 0 Tachycardia: 0 Bradycardia: 0
Virkkila, Ali-Melkkila, and Kanto, 1993 | 4 | IM | | Hypertension: 0 HR >100: 0 Tachycardia: 0 Bradycardia: 14
Virkkila, Ali-Melkkila, and Kanto, 1993 | 5 | IM | | Hypertension: 0 HR >100: 0 Tachycardia: 0 Bradycardia: 0
Virkkila, Ali-Melkkila, Kanto et al., 1994 | 1 | IM | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | HR >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Virkkila, Ali-Melkkila, Kanto et al., 1994 | 2 | IM | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | HR >100: 0 Tachycardia: 0 Bradycardia: 7 Supplemental O2: 0
Virkkila, Ali-Melkkila, Kanto et al., 1994 | 3 | IM | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | HR >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Zehetmayer, Radax, Skorpik et al., 1996 | 1 | Oral | Orbital hemorrhage: 0
Zehetmayer, Radax, Skorpik et al., 1996 | 2 | Oral | Orbital hemorrhage: 3
Zehetmayer, Rainer, Turnheim et al., 1997 | 1 | Oral | Corneal staining: 12
Zehetmayer, Rainer, Turnheim et al., 1997 | 2 | Oral | Corneal staining: 6

Evidence Table 46. Sedation: Summary of evidence on the effectiveness of intravenous sedation regarding patient cooperation and pain

Author(s)/year | Group | Class of agent | Surgeon assessment of cooperation | Anesthesia observer assessment of cooperation | % with no pain during A: block B: surgery | % with mild/moderate pain during A: block B: surgery | % with severe pain A: block B: surgery | Mean pain score (0-10) A: block B: surgery | Median pain score (0-10) A: block B: surgery
Anderson, 1995 | 1 | Benzodiazepine | | | B: 90
Anderson, Nath, and Anderson, 1999 | 1 | Benzodiazepine | | | B: 88 | B: 13
Anderson, Nath, and Anderson, 1999 | 2 | Benzodiazepine | | | B: 88 | B: 13
Ellingsson and Aasved, 1979 | 1 | Benzodiazepine | 43
Ellingsson and Aasved, 1979 | 2 | Benzodiazepine | 5
Ellingsson and Aasved, 1979 | 3 | Benzodiazepine | 16
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | Benzodiazepine | 21
Vettese and Breslin, 1985 | 1 | Benzodiazepine | 12
Vettese and Breslin, 1985 | 2 | Benzodiazepine | 15
Vettese and Breslin, 1985 | 3 | Benzodiazepine | 15
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | Benzodiazepine | | | | | | A: 44.7
Wong and Merrick, 1996 | 2 | Benzodiazepine | | | | | | | A: 1.2
Patel, Burns, Crandall et al., 1996 | 2 | Barbiturates | 67 | | A: 96 B: 91 | A: 4 B: 9 | | A: 0.2 B: 0.2 | A: 0.1 B: 0
Patel, Clinch, Burns et al., 1998 | 2 | Barbiturates | 45 | | A: 82 B: 89 | A: 18 B: 11 | B: 0 | A: 0.33 B: 0.2 | A: 0 B: 0
Pappa, Pouliou, Nastou et al., 1995 | 1 | Analgesics | | | | | A: 0 | A: 1.85
Pappa, Pouliou, Nastou et al., 1995 | 2 | Analgesics | | | | | A: 50 | A: 3
Sarvela and Nikki, 1992a | 1 | Analgesics | | | B: 83
Sarvela and Nikki, 1992a | 2 | Analgesics | | | B: 94
Sarvela, Nikki, and Paloheimo, 1993 | 1 | Analgesics | | | | | | | A: 18
Sarvela, Nikki, and Paloheimo, 1993 | 2 | Analgesics | | | | | | | A: 1.6
Sarvela, Nikki, and Paloheimo, 1993 | 3 | Analgesics | | | | | | | A: 1.4
Sarvela, Nikki, and Paloheimo, 1993 | 4 | Analgesics | | | | | | | A: 1.7
Uusitalo, Maunuksela, Paloheimo et al., 1999 | 1 | Analgesics | | | B: 70 | B: 26 | B: 4 | A: 0.9 B: 0.8
Uusitalo, Maunuksela, Paloheimo et al., 1999 | 2 | Analgesics | | | B: 93 | B: 7 | B: 0 | A: 0.7 B: 0.1
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | Analgesics | | | | | | A: 3.5
Wong and Merrick, 1996 | 3 | Analgesics | | | | | | | A: 0.8
Gillart, Bazin, Montetagaud et al., 1998 | 1 | Propofol | | | A: 46 | A: 54 | A: 0
Gillart, Bazin, Montetagaud et al., 1998 | 2 | Propofol | | | A: 46 | A: 49 | A: 6
Gillart, Bazin, Montetagaud et al., 1998 | 3 | Propofol | | | A: 51 | A: 46 | A: 3
Gillart, Bazin, Montetagaud et al., 1998 | 4 | Propofol | | | A: 40 | A: 54 | A: 6
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | Propofol | 24
Yee, Burns, Mann et al., 1996 | 1 | Propofol | | 10
John, 1998 | 1 | Benzodiazepine Propofol | 51
John, 1998 | 2 | Benzodiazepine Propofol | 51
Yee, Burns, Mann et al., 1996 | 2 | Analgesics Propofol | | 10
Yee, Burns, Mann et al., 1996 | 3 | Analgesics Propofol | | 10
Yee, Burns, Mann et al., 1996 | 4 | Analgesics Propofol | | 10
Gilbert, Holt, Johnston et al., 1987 | 1 | Benzodiazepine Analgesics | 20
Kothari, Shah, Shah et al., 1998 | 1 | Benzodiazepine Analgesics | | | B: 74 | B: 26 | B: 0
Patel, Burns, Crandall et al., 1996 | 1 | Benzodiazepine Analgesics | 67 | | A: 41 B: 96 | A: 58 B: 4 | A: 0 | A:1.1 B:1.2 | A: 1.1 B: 1
Patel, Clinch, Burns et al., 1998 | 1 | Benzodiazepine Analgesics | 41 | | A: 62 B: 69 | A: 38 B: 31 | B: 0 | A: 0.78 B: 0.78 | A: 0 B: 0
Rosenberg, Raymond, and Bridge, 1995 | 2 | Benzodiazepine Analgesics | | 18
Wong and Merrick, 1996 | 4 | Benzodiazepine Analgesics | | | | | | | A: 0.6
Gilbert, Holt, Johnston et al., 1987 | 2 | Barbiturates Analgesics | 27
Rosenberg, Raymond, and Bridge, 1995 | 1 | Barbiturates Analgesics | | 11
Ibrahim and Savino, 1974 | 1 | Benzodiazepine Barbiturates Analgesics Other IV | 25 | 28 | B: 63
Ibrahim and Savino, 1974 | 2 | Barbiturates Analgesics Other IV | 26 | 27 | B: 63

Evidence Table 47. Sedation: Summary of evidence on the effectiveness of intravenous sedation regarding patient anxiety and satisfaction

Author(s)/year | Group | Class of agent | Anxiety (% of patients reporting) | | Patient satisfaction (% of patients reporting) | | | | | % desiring management again
Author(s)/year | Group | Class of agent | None | Severe | Excellent | Very good | Good | Fair | Poor | % desiring management again
Wong and Merrick, 1996 | 2 | Benzodiazepine | | | 100
el-Bassiouny, el-Taher, and el-Din, 1992 | 1 | Analgesics | | | 95 | | | | 5
el-Bassiouny, el-Taher, and el-Din, 1992 | 2 | Analgesics | | | 60 | | | | 40
Uusitalo, Maunuksela, Paloheimo et al., 1999 | 1 | Analgesics | | | | | | 4 | 1
Uusitalo, Maunuksela, Paloheimo et al., 1999 | 2 | Analgesics | | | | | | 4 | 0
Wong and Merrick, 1996 | 3 | Analgesics | | | 100
Cruise, Chung, Yogendran et al., 1997 | 1 | Analgesics Propofol | | | | | | | | 67
Cruise, Chung, Yogendran et al., 1997 | 2 | Analgesics Propofol | | | | | | | | 21
Cruise, Chung, Yogendran et al., 1997 | 3 | Analgesics Propofol | | | | | | | | 23
Cruise, Chung, Yogendran et al., 1997 | 4 | Analgesics Propofol | | | | | | | | 67
Kost and Emerson, 1992 | 1 | Analgesics Propofol | | | 30 | | 68 | 3
Gilbert, Holt, Johnston et al., 1987 | 1 | Benzodiazepine Analgesics | | | 43 | | 46 | | 11
Kost and Emerson, 1992 | 2 | Benzodiazepine Analgesics | | | 3 | | 92 | 5
Wong and Merrick, 1996 | 4 | Benzodiazepine Analgesics | | | 100
Gilbert, Holt, Johnston et al., 1987 | 2 | Barbiturates Analgesics | | | 74 | | 22 | | 4
Ibrahim and Savino, 1974 | 1 | Benzodiazepine Barbiturates Analgesics | 78 | 3
Ibrahim and Savino, 1974 | 2 | Benzodiazepine Barbiturates Analgesics | 74 | 6

Evidence Table 48. Sedation: Summary of evidence on the effectiveness of intravenous sedation regarding medical outcomes and complications

Author(s)/year | Group | Class of agent | Medical complications (% with) | Hemodynamic complications (% with)
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | Benzodiazepine | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 4
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | Benzodiazepine | | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Wong and Merrick, 1996 | 2 | Benzodiazepine | | Supplemental O2: 0
Yee, Schafer, Crandall et al., 1994 | 1 | Barbiturates | | Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | Analgesics | | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Wong and Merrick, 1996 | 3 | Analgesics | | Supplemental O2: 23
Yee, Schafer, Crandall et al., 1994 | 2 | Analgesics | | Supplemental O2: 7
Herrick, Gelb, Nichols et al., 1996 | 1 | Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 4
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | Propofol | | Hypertension: 0 Supplemental O2: 0
Yee, Burns, Mann et al., 1996 | 1 | Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 20
Yee, Burns, Mann et al., 1996 | 2 | Analgesics Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 10
Yee, Burns, Mann et al., 1996 | 3 | Analgesics Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Yee, Burns, Mann et al., 1996 | 4 | Analgesics Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 40
Chung, Cheng, Seyone et al., 1990 | 1 | Benzodiazepine Analgesics | | Supplemental O2: 0
Chung, Cheng, Seyone et al., 1990 | 2 | Benzodiazepine Analgesics | | Supplemental O2: 0
Gilbert, Holt, Johnston et al., 1987 | 1 | Benzodiazepine Analgesics | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0
Rosenberg, Raymond, and Bridge, 1995 | 2 | Benzodiazepine Analgesics | | Heart rate >100: 25 Tachycardia: 0
Wong and Merrick, 1996 | 4 | Benzodiazepine Analgesics | | Supplemental O2: 7
Gilbert, Holt, Johnston et al., 1987 | 2 | Barbiturates Analgesics | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0
Rosenberg, Raymond, and Bridge, 1995 | 1 | Barbiturates Analgesics | | Heart rate >100: 30 Tachycardia: 0
Khalil, Howard, Mankarious et al., 1998 | 2 | Barbiturates Other IV | | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Khalil, Howard, Mankarious et al., 1998 | 3 | Barbiturates Other IV | | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Virkkila, Ali-Melkkila, Kanto et al., 1994 | 3 | Benzodiazepine Other IV | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Khalil, Howard, Mankarious et al., 1998 | 1 | Barbiturates Analgesics Other IV | | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 5 Supplemental O2: 0

Evidence Table 49. Sedation: Comparison of intravenous agents regarding patient cooperation and pain

Author(s)/year | Group | Class of agent | Surgeon assessment of cooperation | Anesthesia observer assessment of cooperation | % with no pain during A: block B: surgery | % with mild/moderate pain during A: block B: surgery | % with severe pain during A: block B: surgery | Mean pain score (0-10) A: block B: surgery | Median pain score (0-10) A: block B: surgery
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | Benzodiazepine | 21
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | Propofol | 24
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | Analgesics | | | | | | A: 3.5
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | Benzodiazepine | | | | | | A: 4.5
Wong and Merrick, 1996 | 2 | Benzodiazepine | | | | | | | A: 1
Wong and Merrick, 1996 | 3 | Analgesics | | | | | | | A: 1
Wong and Merrick, 1996 | 4 | Benzodiazepine Analgesics | | | | | | | A: 1
Patel, Burns, Crandall et al., 1996 | 1 | Benzodiazepine Analgesics | 67 | | A: 41 B: 83 | A: 58 B: 17 | A: 0 | A: 1.1 B: 0.2 | A: 1 B: 1
Patel, Burns, Crandall et al., 1996 | 2 | Barbiturates | 67 | | A: 96 B: 91 | A: 4 B: 9 | A: 0 | A: 0 B: 0 | A: 0 B: 0
Patel, Clinch, Burns et al., 1998 | 1 | Benzodiazepine Analgesics | 41 | | A: 62 B: 69 | A: 38 B: 31 | B: 0 | A: 0.78 B: 0.78 | A: 0 B: 0
Patel, Clinch, Burns et al., 1998 | 2 | Barbiturates | 45 | | A: 82 B: 89 | A: 18 B: 11 | B: 0 | A: 0.33 B: 0.2 | A: 0 B: 0
Roman, Auclin, and Ullern, 1996 | 1 | Analgesics Propofol | | | A: 78 B: 96 | A: 22 B: 4 | A: 0 | A: 0 | A: 0
Roman, Auclin, and Ullern, 1996 | 2 | Propofol | | | A: 100 B: 93 | A: 0 B: 7 | A: 0 | A: 0 | A: 0
Yee, Burns, Mann et al., 1996 | 1 | Propofol | | 10
Yee, Burns, Mann et al., 1996 | 2 | Analgesics Propofol | | 10
Yee, Burns, Mann et al., 1996 | 3 | Analgesics Propofol | | 10
Yee, Burns, Mann et al., 1996 | 4 | Analgesics Propofol | | 10
Gilbert, Holt, Johnston et al., 1987 | 1 | Benzodiazepine Analgesics | 20
Gilbert, Holt, Johnston et al., 1987 | 2 | Barbiturates Analgesics | 27
Rosenberg, Raymond, and Bridge, 1995 | 1 | Barbiturates Analgesics | | 11
Rosenberg, Raymond, and Bridge, 1995 | 2 | Benzodiazepine Analgesics | | 18

Evidence Table 50. Sedation: Comparison of intravenous agents regarding anxiety control and satisfaction

Author(s)/year | Group | Class of agent | Anxiety (% of patients reporting) | | | Patient satisfaction (% of patients reporting) | | | | % desiring management again
Author(s)/year | Group | Class of agent | None | Mild/moderate | Severe | Excellent | Good | Fair | Poor | % desiring management again
Wong and Merrick, 1996 | 2 | Benzodiazepine | | | | 100
Wong and Merrick, 1996 | 3 | Analgesics | | | | 100
Wong and Merrick, 1996 | 4 | Benzodiazepine Analgesics | | | | 100
Roman, Auclin, and Ullern, 1996 | 1 | Analgesics Propofol | | | | | | | | 13
Roman, Auclin, and Ullern, 1996 | 2 | Propofol | | | | | | | | 62
Kost and Emerson, 1992 | 1 | Analgesics Propofol | | | | 30 | 68 | 3 | 0
Kost and Emerson, 1992 | 2 | Benzodiazepine Analgesics | | | | 3 | 92 | 5 | 0

Evidence Table 51. Sedation: Comparison of intravenous agents regarding medical complications and hemodynamics

Author(s)/year | Group | Class of agent | Medical complications (% with) | Hemodynamic complications (% with)
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | Benzodiazepine | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 4
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | Propofol | | Hypertension: 0 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 1 | Analgesics | | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Virkkila, Ali-Melkkila, and Kanto, 1992 | 2 | Benzodiazepine | | Hypertension: 0 Tachycardia: 0 Bradycardia: 3 Supplemental O2: 0
Wong and Merrick, 1996 | 2 | Benzodiazepine | | Supplemental O2: 0
Wong and Merrick, 1996 | 3 | Analgesics | | Supplemental O2: 23
Wong and Merrick, 1996 | 4 | Benzodiazepine Analgesics | | Supplemental O2: 7
Roman, Auclin, and Ullern, 1996 | 1 | Analgesics Propofol | Eye bruise: 4
Roman, Auclin, and Ullern, 1996 | 2 | Propofol | Eye bruise: 0
Yee, Burns, Mann et al., 1996 | 1 | Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 20
Yee, Burns, Mann et al., 1996 | 2 | Analgesics Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 10
Yee, Burns, Mann et al., 1996 | 3 | Analgesics Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Yee, Burns, Mann et al., 1996 | 4 | Analgesics Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 40
Gilbert, Holt, Johnston et al., 1987 | 1 | Benzodiazepine Analgesics | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0
Gilbert, Holt, Johnston et al., 1987 | 2 | Barbiturates Analgesics | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0
Khalil, Howard, Mankarious et al., 1998 | 1 | Barbiturates Analgesics | | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 5 Supplemental O2: 0
Khalil, Howard, Mankarious et al., 1998 | 2 | Barbiturates | | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Khalil, Howard, Mankarious et al., 1998 | 3 | Barbiturates | | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Rosenberg, Raymond, and Bridge, 1995 | 1 | Barbiturates Analgesics | | Heart rate >100: 30 Tachycardia: 0
Rosenberg, Raymond, and Bridge, 1995 | 2 | Benzodiazepine Analgesics | | Heart rate >100: 25 Tachycardia: 0

Evidence Table 52. Sedation: Safety and effectiveness of patient-controlled anesthesia regarding pain and cooperation

Author(s)/year | Group | Planned sedation | Surgeon assessment of cooperation | % with no pain during A: block B: surgery | % with severe pain during A: block B: surgery | Mean pain score (0-10) A: block B: surgery
Pac-Soo, Deacock, Lockwood et al., 1996 | 1 | PCA Placebo | 25
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | PCA Benzodiazepine | 21
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | PCA Propofol | 24

Evidence Table 53. Sedation: Safety and effectiveness of patient-controlled anesthesia regarding medical complications and hemodynamics

Author(s)/year | Group | Planned sedation | Medical complications (% with) | Hemodynamic complications (% with)
Herrick, Gelb, Nichols et al., 1996 | 1 | PCA Propofol | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 4
Herrick, Gelb, Nichols et al., 1996 | 2 | Placebo | MI: 0 CHF: 0 Ventricular arrhythmia: 0 Arrhythmia N.S.: 0 Stroke: 0 TIA: 0 Respiratory failure: 0 Hospitalized: 0 | Hypertension: 0 Heart rate >100: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Pac-Soo, Deacock, Lockwood et al., 1996 | 1 | PCA Placebo | | Hypertension: 4 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 0
Pac-Soo, Deacock, Lockwood et al., 1996 | 2 | PCA Benzodiazepine | | Hypertension: 0 Tachycardia: 0 Bradycardia: 0 Supplemental O2: 4
Pac-Soo, Deacock, Lockwood et al., 1996 | 3 | PCA Propofol | | Hypertension: 0 Supplemental O2: 0