# Acronyms and Abbreviations Used in the Evidence Tables

Acronyms and Abbreviations Used in the Evidence Tables

ASA | American Society of Anesthesiology surgical risk classification
BP | Blood pressure
BRADY | Treated for bradycardia
BSA | Brainstem anesthesia
CHF | New or worsened congestive heart failure
CME | Cystoid macular edema
CNS | Central nervous system
ECCE | Extracapsular cataract extraction
EKG | Electrocardiogram
EOM | Extraocular muscle
HEMO | Hemodynamics
h/o | History of
HOSP | Hospitalization due to complications
HR | Heart rate
HR>100 | Heart rate greater than 100 beats per minute
HTN | Treated for hypertension
ICCE | Intracapsular cataract extraction
IM | Intramuscular
IOP | Intraocular pressure
IV | Intravenous
MAP | Mean arterial pressure
MI | Myocardial infarction
N/A | Not applicable
NRT | Nonrandomized controlled trial
N.S. | Not specified
NSARR | Other nonsinus arrhythmia
OR | Operating room
PCA | Patient-controlled anesthesia
PCS | Patient-controlled sedation
PCR | Posterior capsule rupture and/or vitrectomy
PE | Phacoemulsification
PTO | Ptosis
RCT | Randomized controlled trial
RF | Respiratory failure
RG | Ruptured globe
RH | Retrobulbar hemorrhage
SPO2 | Supplemental oxygen (oxygen saturation less than 90 percent)
STR | Strabismus
TACH | Treated for tachycardia
TIA | Transient ischemic attack
UK | United Kingdom
VARR | Ventricular arrhythmia
VAS | Visual analogue scale
X-SEC | Cross-sectional study design