# Supplemental Analyses

## Decision Analysis of Cataract Surgery Anesthesia Management Strategies

### Objective

Review of the available evidence showed no explicit comparisons of the risks, benefits, and costs of different models of anesthesia care for cataract surgery (e.g., topical versus regional block and oral versus intravenous sedation). Additionally, practice patterns used both nationally and internationally for the provision of intravenous sedation/anesthesia have not been evaluated in any prospective fashion. In the absence of explicit data, a decision analysis was constructed to explore the potential cost effectiveness of different models of anesthesia care. Decision analysis is an analytic tool designed to facilitate complex clinical, therapeutic, or diagnostic decisions in which many variables must be considered simultaneously. The analysis performed here is an attempt to assess the economic impact, as well as the benefits and risks to the patient, of different anesthesia management strategies for cataract surgery as an exploratory process to guide future research. We chose to examine anesthesia strategies that are prevalent internationally. A manuscript describing this work (Reeves, Fleisher, Friedman et al.) is now in preparation for print.

### Design

To perform the decision analysis, we: (1) identified the problem and defined alternative courses of action; (2) constructed a decision tree; (3) gathered relevant information to fill the tree; (4) performed calculations to analyze the tree in order to determine the optimum strategy; and (5) performed sensitivity analyses to assess the stability of the analysis to the assumptions (Petitti, 1994). Sensitivity analysis is an explicit means of assessing the robustness of our conclusions to uncertainty in the values used in our model.

The decision model for the analysis was developed in DATA 3.5 (Treeage Software, Boston, Massachusetts). The authors of this report developed the scenarios by an interactive process in collaboration with external consultants. Baseline scenarios included local block (either retrobulbar or peribulbar block) or topical anesthesia (including intracameral anesthesia). For both the block and topical anesthesia alternatives, sedation strategies of intravenous and oral medications were included. Finally, strategies with an anesthesiologist in the operating room, "on call," or "not present and unavailable" were assessed. In the scenarios, an "on call anesthesiologist" referred to an anesthesiologist present in the operating suite and immediately available to provide sedation/monitoring/resuscitation but not specifically assigned to be present in the operating room during the procedure. For the sake of simplicity, an anesthesiologist was defined as the provider of anesthesia care. There are multiple potential models of anesthesia care, including an anesthesiologist, an anesthesiologist/certified registered nurse anesthetist (CRNA) care team, or a CRNA working under the medical direction of the ophthalmologist. These were not separately assessed. A total of six clinically relevant strategies were chosen:

Strategy 1: Intravenous (IV) sedation administered by an anesthesiologist and block (retrobulbar or peribulbar) anesthesia intraoperatively, with an anesthesiologist present in the operating room throughout the procedure.

Strategy 2: Oral sedation preoperatively and block anesthesia intraoperatively, with an anesthesiologist on call for additional sedation if needed.

Strategy 3: Oral sedation preoperatively and block anesthesia intraoperatively, with no anesthesiologist on call for additional sedation.

Strategy 4: Intravenous sedation administered by an anesthesiologist and topical anesthesia intraoperatively, with an anesthesiologist in the room for monitoring and for additional sedation.

Strategy 5: Oral sedation preoperatively and topical anesthesia intraoperatively, with an anesthesiologist on call for additional sedation.

Strategy 6: Oral sedation preoperatively and topical anesthesia intraoperatively, with no anesthesiologist on call for additional sedation.

For each general strategy, potential outcomes of the anesthesia strategy included no complications, conversion to general anesthesia, or conversion from topical anesthesia to an ocular block by injection. Adverse events included in the model were complications requiring admission within one week, cardiovascular instability intraoperatively, or nausea and vomiting postoperatively. Probabilities for possible outcomes were assigned based upon the available literature. If no data were available in the literature, then data from the Study of Medical Testing for Cataract Surgery (SMTCS) were used. If information was still unavailable on the probabilities of different outcomes, a group of eight clinical experts, including anesthesiologists, ophthalmologists, and internists, were asked to assign probabilities based on clinical judgment. Risks of rare major complications, such as total spinal anesthesia related to performance of a retrobulbar injection and death, were not included in the model since the rates of these complications for the different baseline anesthesia strategies could not be estimated from any available sources and are extremely low.

Preference values for the six anesthesia management strategies were determined based upon the responses of 10 health care providers, including anesthesiologists, nurse anesthetists, ophthalmologists, and internists. The experts were asked to rate the anesthesia strategies described above using a score from 0 to 100, with 0 representing the worst possible experience during cataract surgery and 100 representing the ideal experience. The highest and lowest responses were used to determine a plausible range in the sensitivity analysis. The decrease in preference value (i.e., disutility factor) due to a complication was determined by asking the experts to assign preference values to anesthesia management scenarios that included a complication. We calculated a disutility factor for each complication by dividing the preference value assigned to the strategy with the complication by the preference value assigned to the scenario without the complication. The plausible range for the disutility factor was based on the lowest and highest values assigned by individual experts. Importantly, the preference values and disutility factors used for this analysis do not represent traditional utilities, in that perfect health and death were not the anchors. However, it would not have been possible to differentiate adequately among the anesthesia strategies if we had used perfect health and death as the anchors for assigning preference values to the strategies.

### Cost Considerations

Cost estimates are best based on a single payer's perspective. For the case of sedation during cataract surgery, the primary payer is Medicare. However, Medicare pays a capitated fee for services based on diagnosis-related groups (DRGs), making it difficult to evaluate the true cost of different anesthesia management strategies. DRG fees are based on the average cost of the typical approach being used by physicians and hospitals. Because the adoption by physicians and hospitals of more expensive approaches will ultimately lead to increases in the DRG fees, we used the provider's perspective in calculating costs. Ultimately, incremental costs incurred by more expensive management strategies may be reflected in what Medicare pays for anesthesia care.

The costs used in the model were based on costs from The Johns Hopkins Hospital and the average wholesale price for drugs. Since there are administrative costs for the use of pharmaceutical agents during anesthesia, we used twice the average wholesale price to estimate these added costs.

The cost of the anesthesia provider was based upon the current prevailing rate of a per diem anesthesiologist of $1,000 per day with an average work day of 10 hours, attending approximately 10 cataract surgeries. Therefore, the baseline cost was $100 and varied from $75 to $150. There are no data to estimate the cost of having one anesthesiologist immediately available for emergencies but not specifically assigned to an anesthesia case (on call) since this is currently not a reimbursable model used by the Health Care Financing Administration. As a means of estimating these costs, we developed a theoretical model assuming a maximum coverage ratio for a single-center cataract anesthesia site with one anesthesiologist present. Since an average site would have four rooms, we assumed that the average anesthesiologist cost would be $25 per surgery (one-fourth of the above estimate of $100 per surgery for having an anesthesiologist present throughout the case). We estimated a maximum coverage of eight rooms and varied the costs from $9.30 ($75 divided by eight rooms) to $37.50 ($150 divided by four rooms).

As described previously, for calculations, we assumed an anesthesiologist was the provider of anesthesia care, although multiple models of anesthesia care from a personnel standpoint are possible. Since the Health Care Financing Administration currently reimburses these models similarly, we performed a sensitivity analysis around the cost of the anesthesiologist in an attempt to define these variable costs and incorporate the potential costs of these alternative staffing models.

The cost of anesthesia supplies was based upon the hospital anesthesia supply fee at The Johns Hopkins Hospital multiplied by the Medicare cost-to-charge ratio. The cost of preoperative testing was the charge associated with the average number and type of tests used in the Study of Medical Testing for Cataract Surgery, converting hospital charges to costs using the Medicare cost-to-charge ratio. The costs of all of the drugs were based upon the most commonly administered medications for an average 45-minute case using the methodology noted above.

### Decision Analysis Assumptions

Several assumptions were made in designing the final decision tree (Appendix P). We assumed that conversion to general anesthesia is a rare enough event to be mutually exclusive of conversion to block anesthesia from topical anesthesia. Also, we assumed that complications which would require admission postoperatively are mutually exclusive of uncomplicated intraoperative cardiovascular instability and nausea and vomiting postoperatively. We assumed that the decrease in preference value (e.g., disutility) associated with the complication of being converted to general anesthesia would be the same for strategies 1, 2, and 3 (block anesthesia with different sedation strategies). Likewise, we assumed that the disutility associated with the complication of being converted to block from an initial choice of topical anesthesia would be the same for strategies 4, 5, and 6 (topical anesthesia with different sedation strategies). We assumed that the disutilities associated with the complications of postoperative admission, postoperative nausea and vomiting, and intraoperative cardiovascular instability would be the same for all six anesthesia strategies.

When considering the probability of conversion to general anesthesia, the probability of conversion for patients receiving intravenous sedation and block was assumed to be the same as for patients receiving intravenous sedation and topical anesthesia, and the probability of conversion for patients receiving oral sedation and block was assumed to be the same for patients receiving oral sedation and topical anesthesia. Lastly, when considering the probability of conversion to block after initially receiving topical anesthesia, the probability of conversion was assumed to be the same for those patients receiving intravenous sedation and those receiving oral sedation.

The probabilities, patient preference values, and costs assigned to the tree are shown in Decision Analysis Tables 1 through 3 (Appendix Q). The tree is shown in Appendix P.

### Decision Analysis Results

#### Computation of Expected Cost and Sensitivity Analysis

The probabilities and estimated costs were inserted into the tree, and the expected cost was computed for each management strategy. The strategy of least expected cost was found to be strategy 3, block anesthesia with oral sedation preoperatively, with no anesthesiologist/nurse anesthetist present in the operating room (OR) or on call (Decision Analysis Table 4). This strategy was only marginally less costly than strategy 6, topical anesthesia with oral sedation preoperatively, with no anesthesiologist available ($17.16 versus $17.46).

One-way sensitivity analysis of the expected costs was performed. The cost and probability of each variable were varied across its entire plausible range while all other variables were held constant. For a particular variable to be "sensitive" in a one-way sensitivity analysis, a strategy other than strategy 3 would be least expensive for some value of the variable within its plausible range. No variables of cost or probability were found to be sensitive within their plausible ranges for this tree, except that strategy 6 would cost less than strategy 3 if the cost of topical anesthesia was more than $0.30 less than the cost of block anesthesia.

#### Computation of Expected Preference Values and Sensitivity Analysis

The probabilities and preference values for baseline strategies and potential complications were inserted into the tree, and the average expected preference value of each management strategy was computed. The strategy producing the greatest average expected preference value was found to be strategy 1, block anesthesia with IV sedation administered by an anesthesiologist in the room (Decision Analysis Table 5). However, all of the strategies overlap significantly when using the entire plausible range of preference values assigned to the six baseline scenarios by the clinical experts. Therefore, the model is highly sensitive to these estimates.

#### Incremental Gain of Different Strategies

Appendix R is a graph of the average expected cost versus the average expected preference value for each of the six anesthesia strategies. The graph shows that strategy 2 (oral sedation given preoperatively and block anesthesia intraoperatively, with an anesthesiologist on call for additional sedation if needed) is superior to all strategies except strategy 1 because the cost is virtually the same but the average expected preference value is higher. Strategy 1 is significantly more costly, but it has a higher average expected preference value than strategy 2. Whether the additional cost of having an anesthesiologist present to administer intravenous medications is justified depends on the value of the marginal increase in patient "utility." Further research is needed to address this issue.

### Decision Analysis Conclusion

Our decision analysis evaluated several different approaches to the delivery of anesthesia care during cataract surgery in an attempt to clarify the tradeoffs involved. We chose to evaluate traditional approaches to care as well as practice patterns not commonly employed in the United States but followed elsewhere at this time (i.e., anesthesiologist on call). The factors which had the greatest impact on the decision analysis were the costs of the anesthesiologist and the preference values assigned to the different clinical scenarios.

The decision analysis produced several interesting findings. First, the estimated rate of complications of anesthesia is sufficiently rare in all strategies that complications had a negligible effect on determining the optimal approach. Second, strategies employing a retrobulbar or peribulbar block were preferred over those using topical anesthesia. They consistently were preferred by the expert panel at a similar or lower cost (i.e., they were dominant). This finding was driven by the preference of the expert panel for retrobulbar or peribulbar block over topical anesthesia. The cost of retrobulbar or peribulbar block and topical anesthesia is almost identical. Finally, within the alternative strategies related to retrobulbar or peribulbar block, the availability of an anesthesiologist, either on call or present to provide intravenous sedation during a procedure, was preferred over having no anesthesiologist present. This preference incorporates the respondents' risk aversion for rare complications, which were not modeled in the current decision analysis. Importantly, it is unknown whether the presence of anesthesia caregivers decreases the incidence of rare complications. Intravenous sedation is also associated with some risk. Having an anesthesiologist (and/or nurse anesthetist) attend cataract surgeries, however, was estimated to significantly increase the cost. The cost for this scenario was $324.55, as opposed to $42.16 for the block strategy with oral sedation and the anesthesiologist on call (Appendix R). This additional cost was associated with an increase in the average expected preference value from 0.736 to 0.874. The increased preference elicited from the physician panel most likely reflects the added value the anesthesia provider confers. This value may incorporate increased cooperation by the patient as well as a potential safety margin. This decision analysis did not incorporate the risk of death separately. Spinal or brainstem anesthesia related to administration of a retrobulbar block without the presence of an anesthesia provider may confer a greater risk of major morbidity and mortality; however, it is unknown if the intravenous sedation/anesthesia strategy itself may also confer greater risk. Further research is required to determine whether the additional cost of an anesthesiologist/nurse anesthetist providing intravenous sedation/anesthesia and monitoring is within the threshold that either society or individuals find acceptable.

## Injectable Versus Topical Anesthesia for Cataract Surgery: Patient Perceptions of Pain and Side Effects of Anesthesia

The Study of Medical Testing for Cataract Surgery is a large randomized trial funded by the Agency for Healthcare Research and Quality. The principal aim of this research project is to answer the question, "Does routine preoperative medical testing before cataract surgery reduce perioperative morbidity and mortality?" In addition to the collection of data on adverse medical events, data were also collected on the anesthesia management strategies employed, and patients were asked a series of questions regarding perception of pain and side effects of their anesthesia experience. A manuscript describing the findings related to patient report of pain and side effects of anesthesia has been published (Katz, Feldman, Bass et al., 2000). An abstract summarizing this work follows.

### Objective

The objective of the research is to compare patient reports of intraoperative pain and postoperative side effects between those receiving injectable and those receiving topical anesthesia for cataract surgery with and without sedation.

### Design

The research is designed as a prospective cohort study.

### Participants

The study covers 19,250 men and women age 50 years and older undergoing cataract surgery at nine centers in the United States and Canada between June 1995 and June of 1997.

### Intervention

The intervention is topical or injectable anesthesia with or without sedation.

### Main outcome measures

Patient ratings of intraoperative pain, satisfaction with pain management, and early postoperative side effects (drowsiness, anxiety, and nausea) are given.

Ninety-seven percent of patients were very satisfied with their pain management, and this did not differ by anesthesia type. Nearly 10 percent (9.4 percent) of patients receiving topical anesthesia with no intravenous or oral sedation reported any pain during surgery. After adjusting for age, gender, race, American Society of Anesthesiology risk class, self-reported health status, and duration of surgery, the reporting of any pain during surgery was 66 percent lower for patients receiving injectable local anesthesia without sedation, and 54 percent lower among those receiving injectable anesthesia with sedation. Eighteen percent of sedated patients reported postoperative drowsiness, compared with 11 percent among those who were not sedated. This difference was largely due to oral rather than intravenous sedation. Anxiety was more commonly reported among those receiving injectable anesthesia without sedation than among the other groups. Nausea was more common among those receiving any form of sedation, regardless of whether they had topical or injectable anesthesia.

### Conclusions

The percentage of patients reporting intraoperative pain and early postoperative side effects was small. Satisfaction with pain management did not vary by type of anesthesia, but topical anesthesia was associated with greater reporting of intraoperative pain, regardless of whether oral or intravenous sedation was used. Side effects such as drowsiness and nausea were more likely to be reported if sedation was used, regardless of whether local anesthesia was topical or injectable.

## Medicare Claims Analysis

### Methods

A question raised by the core technical consultants was whether the location of performance of cataract surgery might affect outcome. This issue was not addressed by the published literature.

As part of the supplemental analysis performed for a study funded by the Anesthesia Patient Safety Foundation, the rates of readmission and death after cataract surgery were assessed according to venue of care. A 5-percent random sample of national Medicare claims files from 1994 to 1996 was analyzed. The sample included approximately 1.2 million covered lives. The population covered by the data set is 62 percent female and 90 percent Caucasian. Excluded from the data set are retired railroad workers and health maintenance organization enrollees. Cataract was identified by the presence of Current Procedural Terminology (CPT) codes flagged in Medicare Part B claims. Surgical site was defined as either inpatient hospital, outpatient hospital, freestanding ambulatory surgical center, or office according to coding of location of care in the claims files. Admission was defined as return after discharge to an inpatient hospital.

### Results

Table 1 in Appendix S illustrates the rate of readmission within 1 to 7 days of surgery for patients who underwent their cataract surgery as an inpatient, as an outpatient at a hospital, at ambulatory surgery centers, and at office-based settings.

A logistic regression equation was developed to predict readmission within 30 days of surgery. The logistic regression adjusted for age (65-69, 70-74, 75-79, 80-84, 85-89, and 85 or more years old), previous medical admissions to an inpatient hospital during the 6 months prior to the surgery, and the Charlson index of comorbidity (Charlson, Pompei, Ales et al., 1987). Factors which significantly predicted an increased rate of readmission were determined compared to a reference standard of a 65- to 69-year-old male having the cataract extraction in an outpatient hospital setting (Table 2, Appendix S). The predictive factors were age greater than 80 years, prior hospital admission, Charlson index, and surgery performed as an inpatient or at an ambulatory surgery center.

### Conclusions

The findings indicate that older patients with increased comorbidity have a greater risk of admission after cataract surgery. Not surprisingly, the rare patient admitted in advance of cataract surgery (often for medical management) is more likely to be readmitted. The ambulatory surgery setting is associated with a lower rate of readmission than a hospital-based setting. Office-based settings have a higher rate of readmission, but the small sample size limits the significance of the finding. Should office-based cataract surgery become more prevalent, it would be important to reevaluate this issue.