# Bibliography

Abelson MB, Mandel E, Paradis A, et al The effect of hyaluronidase on akinesia during cataract surgery Ophthalmic Surg 1989 May 20(5):325 6 2726146
Aboul-Eish E Is general anaesthesia better than local analgesia for cataract extraction? Bull Ophthalmol Soc Egypt 1968 61(65):263 5 5744630
Abrahamson IA, Scioville G Intravenous diazepam as an adjunct to local anesthesia in ophthalmic surgery Ann Ophthalmol 1975 Apr 7(4):567 70 1147500
Agrawal K, Saxena RC, Nath R, et al. Local anesthesia by peribulbar block for cataract extraction in an eye relief camp. A double-masked, randomized controlled trial. Online J Curr Clin Trials. 1993 Mar 19. Doc. No. 40.
Agrawal V, Athanikar NS Single injection, low volume periocular anesthesia in 1,000 cases J Cataract Refract Surg 1994 Jan 20(1):61 3 8133482
Ali-Melkkila T, Virkkila M, Leino K, et al Regional anaesthesia for cataract surgery: Comparison of three techniques Br J Ophthalmol 1993 Dec 77(12):771 3 8110669 504652
Ali-Melkkila TM, Virkkila M, Jyrkkio H Regional anesthesia for cataract surgery: Comparison of retrobulbar and peribulbar techniques Reg Anesth 1992 Jul 17(4):219 22 1515389
Anderson CJ Subconjunctival anesthesia in cataract surgery J Cataract Refract Surg 1995 Jan 21(1):103 5 7722890
Anderson NJ, Nath R, Anderson J Comparison of preservative-free bupivacaine vs lidocaine for intracameral anesthesia: A randomized clinical trial and in vitro analysis Am J Ophthalmol 1999 127(4):393 402 10218691
Arnold PN Prospective study of a single-injection peribulbar technique J Cataract Refract Surg 1992 Mar 18(2):157 61 1564654
Athanikar NS, Agrawal VB One point low volume peribulbar anaesthesia versus retrobulbar anaesthesia. A prospective clinical trial Indian J Ophthalmol 1991 Apr 39(2):48 9 1916978
Barker JP, Vafidis GC, Hall GM Postoperative morbidity following cataract surgery. A comparison of local and general anaesthesia Anaesthesia 1996 May 51(5):435 7 8694154
Barker JP, Vafidis GC, Robinson PN, et al Plasma catecholamine response to cataract surgery: A comparison between general and local anaesthesia Anaesthesia 1991 Aug 46(8):642 5 1887969
Behndig A, Linden C Aqueous humor lidocaine concentrations in topical and intracameral anesthesia J Cataract Refract Surg 1998 Dec 24(12):1598 601 9850897
Bell RW, Butt ZA Warming lidocaine reduces the pain of injection during peribulbar local anaesthesia for cataract surgery Br J Ophthalmol 1995 Nov 79(11):1015 7 8534645 505319
Beri S, Biswas NR, Shende DR, et al Injectable centbucridine and lidocaine hydrochloride for intraocular surgery Ophthalmic Surg Lasers 1997 Dec 28(12):1027 9 9427994
Bjornstrom L, Hansen A, Otland N, et al Peribulbar anaesthesia. A clinical evaluation of two different anaesthetic mixtures Acta Ophthalmol (Copenh) 1994 Dec 72(6):712 4 358319 7747581
Bloomberg LB, Pellican KJ Topical anesthesia using the Bloomberg SuperNumb Anesthetic Ring J Cataract Refract Surg 1995 Jan 21(1):16 20 7722892
Boezaart AP, Berry RA, Laubscher JJ, et al Evaluation of anxiolysis and pain associated with combined peri- and retrobulbar eye block for cataract surgery J Clin Anesth 1998 May 10(3):204 10 9603590
Brady MD, Hustead RR, Robinson RH, et al Dilution of proparacaine in balanced salt solution reduces pain of anesthetic instillation in the eye Reg Anesth 1994 May 19(3):196 8 7999655
Brahma AK, Pemberton CJ, Ayeko M, et al Single medial injection peribulbar anaesthesia using prilocaine Anaesthesia 1994 Nov 49(11):1003 5 7802219
Briggs MC, Beck SA, Esakowitz L Sub-Tenon's versus peribulbar anaesthesia for cataract surgery Eye 1997 11(Pt 5):639 43 9474310
Brydon CW, Basler M, Kerr WJ An evaluation of two concentrations of hyaluronidase for supplementation of peribulbar anaesthesia Anaesthesia 1995 Nov 50(11):998 1000 8678264
Buttery R, Wise G Conal anaesthesia: A new approach to retrobulbar anaesthesia Aust N Z J Ophthalmol 1989 Feb 17(1):63 9 2765283
Campbell DN, Lim M, Muir MK, et al A prospective randomized study of local versus general anaesthesia for cataract surgery Anaesthesia 1993 May 48(5):422 8 8317653
Campbell IT, Sparrow CH, Duthie AM Ophthalmic anaesthesia under gamma-hydroxybutyrate and local analgesia. A method for developing countries Anaesthesia 1972 Jul 27(3):319 26 5041077
Carino NS, Slomovic AR, Chung F, et al Topical tetracaine versus topical tetracaine plus intracameral lidocaine for cataract surgery J Cataract Refract Surg 1998 Dec 24(12):1602 8 9850898
Cataract Management Guideline Panel. Cataract in adults: Management of functional impairment. Clinical Practice Guideline, No. 4. Rockville (MD):U.S. Department of Health and Human Services, Agency for Health Care Policy and Research. 1993 Feb. AHCPR Publication No. 93-0542.
Chapu BA, Ahmed M, Dhar CL Mandrax as a premedication in cataract surgery Indian J Ophthalmol 1977 Apr 25(1):33 4 612589
Charlson ME, Pompei P, Ales KL, et al. A new method for classifying prognostic comorbidity in longitudinal studies: Development and validation. J Chron Dis. 1987;40:373-83. [pmid: 3558716].
Chittenden HB, Meacock WR, Govan JA Topical anaesthesia with oxybuprocaine versus sub-Tenon's infiltration with 2 percent lidocaine for small incision cataract surgery Br J Ophthalmol 1997 Apr 81(4):288 90 9215056 1722170
Chopdar A Sedation for cataract surgery. Comparison of carbrital and neuroleptanalgesia Br J Ophthalmol 1970 Oct 54(10):687 9 4394335 1208023
Chung F, Cheng DC, Seyone C, et al A randomized comparison of midazolam and diazepam injectable emulsion in cataract surgery Can J Anaesth 1990 Jul 37(5):528 33 2197003
Coelho ET, Gomes EB, Martins HS, et al Prilocaine: An old anesthetic agent and a new ophthalmic procedure Ophthalmic Surg 1993 Sep 24(9):612 6 8233336
Coley S, Jones GW, Lassey D, et al A comparison of the effects of alfentanil/droperidol or fentanyl/droperidol on intra-ocular pressure Anaesthesia 1990 Jun 45(6):477 80 2382805
Corboy JM, Jiang X Postanesthetic hypotropia: A unique syndrome in left eyes J Cataract Refract Surg 1997 Nov 23(9):1394 8 9423914
Crandall AS, Zabriskie NA, Patel BC, et al A comparison of patient comfort during cataract surgery with topical anesthesia versus topical anesthesia and intracameral lidocaine Ophthalmology 1999 Jan 106(1):60 6 9917782
Crawford M, Kerr WJ The effect of hyaluronidase on peribulbar block Anaesthesia 1994 Oct 49(10):907 8 7802194
Cruise CJ, Chung F, Yogendran S, et al Music increases satisfaction in elderly outpatients undergoing cataract surgery Can J Anaesth 1997 Jan 44(1):43 8 8988823
Cugini U, Lanzetta P, Nadbath P, et al Sedation with ketamine during cataract surgery J Cataract Refract Surg 1997 Jun 23(5):784 6 9278803
Cummings AB, Konig HL Effect of oxygen and air inhalation during cataract surgery on blood gas parameters J Cataract Refract Surg 1996 Nov 22(9):1236 9 8972376
Davis DB, Mandel MR Posterior peribulbar anesthesia: An alternative to retrobulbar anesthesia J Cataract Refract Surg 1986 Mar 12(2):182 4 3701637
Davis PL, O'Connor JP Peribulbar block for cataract surgery: A prospective double-blind study of two local anesthetics Can J Ophthalmol 1989 Jun 24(4):155 8 2743201
Demirok A, Simsek S, Cinal A, et al Peribulbar anesthesia: One versus two injections Ophthalmic Surg Lasers 1997 Dec 28(12):998 1001 9427987
Dempsey GA, Barrett PJ, Kirby IJ Hyaluronidase and peribulbar block Br J Anaesth 1997 Jun 78(6):671 4 9215017
Dinsmore SC Drop, then decide approach to topical anesthesia J Cataract Refract Surg 1995 Nov 21(6):666 71 8551444
Dinsmore SC Approaching a 100 percent success rate using topical anesthesia with mild intravenous sedation in phacoemulsification procedures Ophthalmic Surg Lasers 1996 Nov 27(11):935 8 8938802
Dopfmer UR, Maloney DG, Gaynor PA, et al Prilocaine 3 percent is superior to a mixture of bupivacaine and lidocaine for peribulbar anaesthesia Br J Anaesth 1996 Jan 76(1):77 80 8672385
Edge KR, McClarty CP, Krige SJ, et al. Comparison of an extraconal block with a retrobulbar-facial block combination for ocular surgery. A safe alternative technique to the combination of retrobulbar block and facial nerve block. S Afr J Surg. 1995 Sep;33.
el-Bassiouny O, el-Taher EM, el-Din ABD Alfentanil/promazine versus meperidine/promazine as a sedative regimens during local analgesia for cataract operation Doc Ophthalmol 1992 82(3):201 10 1303855
Ellingsson A, Aasved H Etidocaine and lidocaine in ophthalmic surgery. Short communication Acta Ophthalmol (Copenh) 1979 Aug 57(4):543 6 358319 393055
Erb T, Sluga M, Hampl KF, et al Preoperative anxiolysis with minimal sedation in elderly patients: Bromazepam or clorazepate-dipotassium? Acta Anaesthesiol Scand 1998 Jan 42(1):97 101 9527752
Feibel RM, Custer PL, Gordon MO Postcataract ptosis. A randomized, double-masked comparison of peribulbar and retrobulbar anesthesia Ophthalmology 1993 May 100(5):660 5 8493007
Fichman RA Use of topical anesthesia alone in cataract surgery J Cataract Refract Surg 1996 Jun 22(5):612 4 8784636
Filos KS, Patroni O, Goudas LC, et al A dose-response study of orally administered clonidine as premedication in the elderly: Evaluating hemodynamic safety Anesth Analg 1993 Dec 77(6):1185 92 8250311
Forrest JB, Lam L, Woo J, et al Oxygen desaturation in elderly patients during cataract surgery Can J Anaesth 1990 May 37(4 Pt 2):
Forrest JB, Lam L, Woo J, et al Recovery after neuroleptanalgesia for cataract surgery Can J Anaesth 1990 May 37(4 Pt 2):
Francis IC, Schumacher RS, Haylen MJ Assisted local anaesthesia for cataract surgery (ALACS) Aust N Z J Ophthalmol 1987 Aug 15(3):185 91 3675910
Fukasaku H, Marron JA Pinpoint anesthesia: A new approach to local ocular anesthesia J Cataract Refract Surg 1994 Jul 20(4):468 71 7932140
Furuta M, Toriumi T, Kashiwagi K, et al Limbal anesthesia for cataract surgery Ophthalmic Surg 1990 Jan 21(1):22 5 2325991
Garbutt JC, West SL, Carey TS, et al Pharmacological treatment of alcohol dependence A review of the evidence. JAMA 1999 281(14):1318 25
Garcia A, Loureiro F, Limao A, et al. Preservative-free lidocaine 1 percent anterior chamber irrigation as an adjunct to topical anesthesia. J Cataract Refract Surg. 1998;24:403-6. [pmid: 9580374].
Ghanchi FD, Khan MY Sublingual lorazepam as premedication in peribulbar anesthesia J Cataract Refract Surg 1997 Dec 23(10):1581 4 9456420
Gilbert J, Holt JE, Johnston J, et al Intravenous sedation for cataract surgery Anaesthesia 1987 Oct 42(10):1063 9 3688387
Gillart T, Bazin JE, Deret C, et al Effect of injection pressure on the success rate of peribulbar block Anaesthesia 1996 Aug 51(8):779 82 8795325
Gillart T, Bazin JE, Montetagaud M, et al The effects of volume and speed of injection in peribulbar anaesthesia Anaesthesia 1998 May 53(5):486 91 9659024
Gills JP, Cherchio M, Raanan MG Unpreserved lidocaine to control discomfort during cataract surgery using topical anesthesia J Cataract Refract Surg 1997 May 23(4):545 50 9209989
Guise PA Single quadrant sub-Tenon's block. Evaluation of a new local anaesthetic technique for eye surgery Anaesth Intensive Care 1996 Apr 24(2):241 4 9133200
Gutman H, Sinskey RM, Cain W A comparison of lidocaine and etidocaine in retrobulbar anesthesia for cataract surgery J Am Intraocul Implant Soc 1979 Apr 5(2):120 2 479003
Hamilton R, Claoue C Topical anesthesia: Proxymetacaine versus amethocaine for clear corneal phacoemulsification J Cataract Refract Surg 1998 Oct 24(10):1382 4 9795856
Hamilton RC Retrobulbar block revisited and revised J Cataract Refract Surg 1996 Nov 22(9):1147 50 8972364
Hamilton RC, Gimbel HV, Strunin L Regional anaesthesia for 12,000 cataract extraction and intraocular lens implantation procedures Can J Anaesth 1988 Nov 35(6):615 23 3203455
Henderson TR, Franks W Peribulbar anaesthesia for cataract surgery: Prilocaine versus lidocaine and bupivacaine Eye 1996 10(Pt 4):497 500 8944106
Hendrick SW, Rosenberg MK, Lebenbom-Mansour MH Efficacy and safety of single injection peribulbar block performed by anesthesiologists prior to cataract surgery J Clin Anesth 1997 Jun 9(4):285 8 9195350
Herrick IA, Gelb AW, Nichols B, et al Patient-controlled Propofol sedation for elderly patients: Safety and patient attitude toward control Can J Anaesth 1996 Oct 43(10):1014 8 8896852
Hinshaw KD, Fiscella R, Sugar J Preparation of pH-adjusted local anesthetics Ophthalmic Surg 1995 May 26(3):194 9 7651682
Hodgkins PR, Teye-Botchway L, Morrell AJ, et al Neuroleptanalgesia and extracapsular cataract extraction Br J Ophthalmol 1992 Mar 76(3):153 6 1540558 504193
Hosal BM, Tekeli O, Gursel E Eyelid malpositions after cataract surgery Eur J Ophthalmol 1998 Jan 8(1):12 5 9590589
House PH, Hollands RH, Schulzer M Choice of anesthetic agents for peribulbar anesthesia J Cataract Refract Surg 1991 Jan 17(1):80 3 2005563
Huha T, Ala-Kokko TI, Salomaki T, et al. Clinical efficacy and pharmacokinetics of 1 percent ropivacaine and 0. 75 percent bupivacaine in peribulbar anesthesia for cataract surgery. Anaesthesia. 1999;54:137-41. [pmid: 10215708].
Hulquist CR Painless wakeful peribulbar block achieved safely with a single transconjunctival injection Ophthalmic Surg 1995 May 26(3):200 4 7651683
Ibrahim WS, Savino PJ Preoperative sedation in cataract surgery: An evaluation of two regimens Ann Ophthalmol 1974 Apr 6(4):387 92 4821370
Johansen J, Kjeldgard M, Corydon L Retrobulbar anaesthesia. A clinical evaluation of four different anaesthetic mixtures Acta Ophthalmol (Copenh) 1993 Dec 71(6):787 90 358319 8154254
John T Simplified anesthesia technique for scleral tunnel phacoemulsification J Cataract Refract Surg 1998 Dec 24(12):1562 5 9850890
Johnston RL, Whitefield LA, Giralt J, et al Topical versus peribulbar anesthesia, without sedation, for clear corneal phacoemulsification J Cataract Refract Surg 1998 Mar 24(3):407 10 9559479
Jolliffe DM, Abdel-Khalek MN, Norton AC A comparison of topical anaesthesia and retrobulbar block for cataract surgery Eye 1997 11(Pt 6):858 62 9537146
Joyce PW, Sunderraj P, Villada J, et al A comparison of amethocaine cream with lidocaine-prilocaine cream (EMLA) for reducing pain during retrobulbar injection Eye 1994 8(Pt 4):465 6 7821475
Kaplan LJ, Jaffe NS, Clayman HM Ptosis and cataract surgery. A multivariant computer analysis of a prospective study Ophthalmology 1985 Feb 92(2):237 42 3982804
Kapran Z, Uyar M, Eltutar K, et al One quadrant sub-Tenon's capsule anesthesia in anterior segment surgery Eur J Ophthalmol 1996 Apr 6(2):131 6 8823584
Karhunen U, Jonn G A comparison of memory function following local and general anaesthesia for extraction of senile cataract Acta Anaesthesiol Scand 1982 Aug 26(4):291 6 7124302
Karhunen U, Orko R Nausea and vomiting after local anesthesia for cataract extraction in elderly female patients -- effect of droperidol premedication Ophthalmic Surg 1981 Nov 12(11):810 2 7322457
Katz J, Feldman LA, Bass EB, et al. Injectable versus topical anesthesia for cataract surgery: Patient perceptions of pain and side effects. Ophthalmology. 2000;107:2054-60. [pmid: 11054331].
Kennerdell JS, Rydze D, Robertson M Comparison of retrobulbar marcaine and combined marcaine-carbocaine in ophthalmic surgery Ann Ophthalmol 1976 Oct 8(10):1236 40 984642
Kershner RM Topical anesthesia for small incision self-sealing cataract surgery. A prospective evaluation of the first 100 patients J Cataract Refract Surg 1993 Mar 19(2):290 2 8487176
Khalil SN, Howard G, Mankarious R, et al Alfentanil decreases the excitatory phenomena of sodium methohexital J Clin Anesth 1998 Sep 10(6):469 73 9793810
Khoo BK, Lim TH, Yong V Sub-Tenon's versus retrobulbar anesthesia for cataract surgery Ophthalmic Surg Lasers 1996 Sep 27(9):773 7 8878196
Khurana AK, Sachdeva RK, Gombar KK, et al Evaluation of subconjunctival anaesthesia vs peribulbar anaesthesia in cataract surgery Acta Ophthalmol (Copenh) 1994 Dec 72(6):727 30 358319 7747584
Kishore K, Agarwal HC, Sood NN, et al Evaluation of peribulbar anesthesia in eye camps Ophthalmic Surg 1990 Aug 21(8):566 70 2234806
Koch PS Anterior chamber irrigation with unpreserved lidocaine 1 percent for anesthesia during cataract surgery J Cataract Refract Surg 1997 May 23(4):551 4 9209990
Kollarits CR, Jaweed S, Kollarits FJ Comparison of pain, motility, and preoperative sedation in cataract phacoemulsification patients receiving peribulbar or sub-Tenon's anesthesia Ophthalmic Surg Lasers 1998 Jun 29(6):462 5 9640566
Kost M, Emerson D Propofol-fentanyl versus midazolam-fentanyl: A comparative study of local sedation techniques for cataract surgery CRNA:The Clinical Forum for Nurse Anesthetists 1992 Feb 3(1):7 15 1477688
Kothari K, Shah J, Shah M, et al Combined topical peribulbar anesthesia for cataract surgery J Cataract Refract Surg 1998 Dec 24(12):1658 60 9850908
Krause M, Weindler J, Ruprecht KW. Does warming of anesthetic solutions improve analgesia and akinesia in retrobulbar anesthesia?. Ophthalmology. 1997;104:429-32. [pmid: 9082268].
Krohn J, Hovding G, Seland JH, et al Retrobulbar anesthesia with and without adrenaline in extracapsular cataract surgery. A prospective, randomized, double-blind study Acta Ophthalmol Scand 1995 Feb 73(1):56 60 7627761
Krohn J, Seland JH, Hovding G, et al Retrobulbar anesthesia with and without hyaluronidase in extracapsular cataract surgery. A prospective, randomized, double-blind study Acta Ophthalmol (Copenh) 1993 Dec 71(6):791 5 358319 8154255
Kumar A, Bose S, Bhattacharya A, et al Oral clonidine premedication for elderly patients undergoing intraocular surgery Acta Anaesthesiol Scand 1992 Feb 36(2):159 64 1549937
Kumar A, Tandon OP, Bhattacharya A, et al Recovery from pre-operative sedation with clonidine -- brain stem auditory evoked response Anaesthesia 1994 Jun 49(6):533 7 8017601
Laaka V, Nikki P, Tarkkanen A Comparison of bupivacaine with and without adrenalin and mepivacaine with adrenalin in intraocular surgery Acta Ophthalmol (Copenh) 1972 50(2):229 39 358319 5068236
Lewis P, Hamilton RC, Brant R, et al Comparison of plain with pH-adjusted bupivacaine with hyaluronidase for peribulbar block Can J Anaesth 1992 Jul 39(6):555 8 1643678
Loots JH, Koorts AS, Venter JA Peribulbar anesthesia. A prospective statistical analysis of the efficacy and predictability of bupivacaine and a lidocaine/bupivacaine mixture J Cataract Refract Surg 1993 Jan 19(1):72 6 8426327
Maclean H, Burton T, Murray A Patient comfort during cataract surgery with modified topical and peribulbar anesthesia J Cataract Refract Surg 1997 Mar 23(2):277 83 9113582
Manners TD, Burton RL Randomized trial of topical versus sub-Tenon's local anaesthesia for small-incision cataract surgery Eye 1996 10(Pt 3):367 70 8796164
Masket S, Gokmen F Efficacy and safety of intracameral lidocaine as a supplement to topical anesthesia J Cataract Refract Surg 1998 Jul 24(7):956 60 9682117
McNamara RL, Bass EB, Miller MR, et al. Management of New Onset Atrial Fibrillation. Evidence Report/ Technology Assessment No. 12. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. 290-97-0006.) AHRQ Publication No. 01-E026. Rockville (MD): Agency for Healthcare Research and Quality. 2001.
Meyer D, Hamilton RC, Loken RG, et al Effect of combined peribulbar and retrobulbar injection of large volumes of anesthetic agents on the intraocular pressure Can J Ophthalmol 1992 Aug 27(5):230 2 1393807
Michelson G, Naujoks B O2 administration by a nasal probe improves respiration in cataract surgery after retrobulbar anesthesia Ophthalmic Surg 1991 Oct 22(10):615 8 1961623
Mindel JS Value of hyaluronidase in ocular surgical akinesia Am J Ophthalmol 1978 May 85(5 Pt 1):643 6 350052
Mjahed K, el Harrar N, Hamdani M, et al Lidocaine-clonidine retrobulbar block for cataract surgery in the elderly Reg Anesth 1996 Nov 21(6):569 75 8956395
Morsman CD, Holden R The effects of adrenaline, hyaluronidase and age on peribulbar anaesthesia Eye 1992 6(Pt 3):290 2 1446762
Muller FO, Claasen JP, Schall R, et al The efficacy of two bupivacaine hydrochloride injection products S Afr Med J 1996 Jun 86(6):667 9 8764423
Murdoch IE Peribulbar versus retrobulbar anaesthesia Eye 1990 4(Pt 3):445 9 2209907
Nathan N, Benrhaiem M, Lotfi H, et al The role of hyaluronidase on lidocaine and bupivacaine pharmacokinetics after peribulbar blockade Anesth Analg 1996 May 82(5):1060 4 8610868
Neatrour GP, Lederman IR Reducing fire hazard during ophthalmic surgery by using compressed air Ophthalmic Surg 1989 Jun 20(6):430 2 2748087
Nicoll JM, Treuren B, Acharya PA, et al Retrobulbar anesthesia: The role of hyaluronidase Anesth Analg 1986 Dec 65(12):1324 8 3777463
Nielsen PJ Immediate visual capability after cataract surgery: Topical versus retrobulbar anesthesia J Cataract Refract Surg 1995 May 21(3):302 4 7674167
Nielsen PJ, Allerod CW Evaluation of local anesthesia techniques for small incision cataract surgery J Cataract Refract Surg 1998 Aug 24(8):1136 44 9719976
Nolan J, Aziz M, Ahmad M, et al Local anesthesia in cataract surgery -- a comparison of different methods Yen Ko Hsueh Pao 1993 Mar 9(1):21 2 8253178
Norregaard JC, Schein OD, Bellan L, et al. International variation in anesthesia care during cataract surgery. Results from the International Cataract Surgery Outcomes Study. Arch Ophthalmol. 1997;115:1304-8. [pmid: 9338678].
Oikkonen M Melperon premedication for cataract surgery. A comparison with diazepam Acta Anaesthesiol Scand 1994 Apr 38(3):211 3 7912875
Oikkonen M, Heine H, Salminen U, et al Dixyrazine premedication for cataract surgery. A comparison with diazepam Acta Anaesthesiol Scand 1994 Apr 38(3):214 7 7912876
Oikkonen M, Reinikainen P. Silent myocardial ischaemia in connection with cataract surgery: Effect of prophylactic oxygenation. Cardiol Elderly. 1996;4:151-5.
Ortiz M, Blanco D, Serra J, et al Peribulbar anaesthesia: The role of local anesthetic volumes and Thiomucase in motor block and intraocular pressure Eur J Anaesthesiol 1995 Nov 12(6):603 7 8665884
Pac-Soo CK, Deacock S, Lockwood G, et al Patient-controlled sedation for cataract surgery using peribulbar block Br J Anaesth 1996 Sep 77(3):370 4 8949813
Palve H, Ali-Melkkila T Oxygenation during local anaesthesia for cataract surgery Acta Anaesthesiol Scand 1991 Feb 35(2):181 4 2024568
Pappa X, Pouliou K, Nastou H, et al EMLA prevents pain during local anesthesia for cataract surgery Acta Anaesthesiol Belg 1995 46(2):75 8 8714853
Patel BC, Burns TA, Crandall A, et al A comparison of topical and retrobulbar anesthesia for cataract surgery Ophthalmology 1996 Aug 103(8):1196 203 8764787
Patel BC, Clinch TE, Burns TA, et al Prospective evaluation of topical versus retrobulbar anesthesia: A converting surgeon's experience J Cataract Refract Surg 1998 Jun 24(6):853 60 9642600
Pecka SL, Dexter F Anesthesia providers' interventions during cataract extraction under monitored anesthesia care Journal of the American Association of Nurse Anesthetists 1997 Aug 65(4):357 60
Petersen WC, Yanoff M Subconjunctival anesthesia: An alternative to retrobulbar and peribulbar techniques Ophthalmic Surg 1991 Apr 22(4):199 201 2057181
Petitti DB. Meta-analysis, decision analysis and cost-effectiveness analysis: Methods for quantitative synthesis in medicine. New York: Oxford University Press; 1994.
Polkinghorne PJ Inadvertent perforation of the globe during regional anaesthesia Aust N Z J Ophthalmol 1996 Feb 24(1):43 5 8743004
Prosser DP, Rodney GE, Mian T, et al Re-evaluation of hyaluronidase in peribulbar anaesthesia Br J Ophthalmol 1996 Sep 80(9):827 30 8942381 505621
Rauz S, Subramaniam S Sub-Tenon's anesthesia and orbicularis oculi function Ophthalmic Surg Lasers 1997 Sep 28(9):727 30 9304634
Redmond RM, Dallas NL Extracapsular cataract extraction under local anaesthesia without retrobulbar injection Br J Ophthalmol 1990 Apr 74(4):203 4 2337543 1042060
Reeves SR, Fleisher LA, Friedman DS, et al. A decision analysis of anesthesia management for cataract surgery. Am J Ophthalmol. in preparation.
Rinkoff JS, Doft BH, Lobes LA Management of ocular penetration from injection of local anesthesia preceding cataract surgery Arch Ophthalmol 1991 Oct 109(10):1421 5 1929933
Risdall JE, Geraghty IF Oxygenation of patients undergoing ophthalmic surgery under local anaesthesia Anaesthesia 1997 May 52(5):492 5 9165972
Robinson K, Hinegardner P, Lansing P. Development of an optimal search strategy for the retrieval of controlled trials using PubMed. Abstr Workshops Sci Sess Int Cochrane Coll. 1998 Oct;6.
Roman S, Auclin F, Ullern M Topical versus peribulbar anesthesia in cataract surgery J Cataract Refract Surg 1996 Oct 22(8):1121 4 8915811
Roman SJ, Chong Sit DA, Boureau CM, et al Sub-Tenon's anaesthesia: An efficient and safe technique Br J Ophthalmol 1997 Aug 81(8):673 6 9349156 1722293
Roper DL, Nisbet RM Effect of hyaluronidase on the incidence of cystoid macular edema Ann Ophthalmol 1978 Dec 10(12):1673 8 367238
Ropo A, Ruusuvaara P, Paloheimo M, et al Periocular anaesthesia: Technique, effectiveness and complications with special reference to postoperative ptosis Acta Ophthalmol (Copenh) 1990 Dec 68(6):728 32 358319 2080707
Rosenberg MK, Raymond C, Bridge PD Comparison of midazolam/ketamine with methohexital for sedation during peribulbar block Anesth Analg 1995 Jul 81(1):173 4 7598251
Rosenfeld SL, Litinsky SM, Snyder DA, et al Effectiveness of monitored anesthesia care in cataract surgery Ophthalmology 1999 106(7):1256 60 10406602
Ruusuvaara P, Setala K, Pajari S, et al Comparison of etidocaine and bupivacaine + lidocaine in retrobulbar anaesthesia Acta Ophthalmol Scand 1995 Dec 73(6):563 6 9019387
Sanchez-Capuchino A, Meadows D, Morgan L Local anaesthesia for eye surgery without a facial nerve block Anaesthesia 1993 May 48(5):428 31 8317654
Sanders R, Ahmed S, Craig EW, et al Comparison of catecholamine and pressor effects in peribulbar and retrobulbar anaesthesia in cataract surgery Eye 1997 11(Pt 5):644 8 9474311
Sanford DK, Minoso Y, Belyea DA Response of intraocular pressure to retrobulbar and peribulbar anesthesia Ophthalmic Surg Lasers 1998 Oct 29(10):815 7 9793946
Sarvela J, Nikki P Hyaluronidase improves regional ophthalmic anaesthesia with etidocaine Can J Anaesth 1992a Nov 39(9):920 4 1451220
Sarvela J, Nikki P Comparison of two needle lengths in regional ophthalmic anesthesia with etidocaine and hyaluronidase Ophthalmic Surg 1992b Nov 23(11):742 5 1484666
Sarvela J, Nikki P, Paloheimo M Orbicular muscle akinesia in regional ophthalmic anaesthesia with pH-adjusted bupivacaine: Effects of hyaluronidase and epinephrine Can J Anaesth 1993 Nov 40(11):1028 33 8269562
Sarvela PJ Comparison of regional ophthalmic anesthesia produced by pH-adjusted 0. 75 percent and 0.5 percent bupivacaine and 1 percent and 1.5 percent etidocaine, all with hyaluronidase Anesth Analg 1993 Jul 77(1):131 4 8317720
Sarvela PJ, Paloheimo MP, Nikki PH Comparison of pH-adjusted bupivacaine 0. 75 percent and a mixture of bupivacaine 0.75 percent and lidocaine 2 percent, both with hyaluronidase, in day-case cataract surgery under regional anesthesia Anesth Analg 1994 Jul 79(1):35 9 8010450
Saunders DC, Sturgess DA, Pemberton CJ, et al Peribulbar and retrobulbar anesthesia with prilocaine: A comparison of two methods of local ocular anesthesia Ophthalmic Surg 1993 Dec 24(12):842 5 8115101
Schimek F, Steuhl KP, Fahle M Retrobulbar blockade of somatic, motor, and visual nerves by local anesthetics Ophthalmic Surg 1993 Mar 24(3):171 80 8483567
Schneider M, Faulborn J, Von Hochstetter AH Posterior peribulbar anaesthesia for eye surgery Eur J Anaesthesiol 1989 Nov 6(6):425 30 2583133
Scott RA, Jakeman CM, Perry SR, et al Peribulbar anaesthesia and needle length J R Soc Med 1995 Oct 88(10):594P 596P
Shammas HJ, Milkie M, Yeo R. Topical and subconjunctival anesthesia for phacoemulsification: Prospective study. J Cataract Refract Surg. 1997;23:1577-80. [pmid: 9456419].
Shibata K, Inage K, Takayama T, et al Use of cold spray for relieving pain from local anesthetic injections in ocular surgery J Ophthalmic Nurs Technol 1993 Jan 12(1):23 30 8487314
Smith PH, Kemp P, Smith ER A comparison of retrobulbar block produced by etidocaine 1 percent and by a mixture of lidocaine 2 percent and bupivacaine 0. 75 percent Ophthalmic Surg 1987 Feb 18(2):106 10 3574862
Smith PH, Kim JW Etidocaine used for retrobulbar block: A comparison with lidocaine Ophthalmic Surg 1980 Apr 11(4):268 73 6992010
Smith PH, Smith ER A comparison of etidocaine and lidocaine for retrobulbar anesthesia Ophthalmic Surg 1983 Jul 14(7):569 74 6888837
Steinberg EP, Javitt JC, Sharkey PD, et al The content and cost of cataract surgery Arch Ophthalmol 1993 111(8):1041 9 8352686
Sunderraj P, Kirby J, Joyce PW, et al A double-masked evaluation of lidocaine-prilocaine cream (EMLA) used to alleviate the pain of retrobulbar injection Br J Ophthalmol 1991 Mar 75(3):130 2 2012777 1042288
Suzuki R, Kawata K, Kuroki S, et al A comparison of blood pressure changes in phacoemulsification surgery with topical and retrobulbar block local anesthesia: Part II Ophthalmologica 1997 211(6):327 31 9380347
Suzuki R, Kuroki S, Fujiwara N A comparison of blood pressure changes in phacoemulsification cataract surgery with topical and retrobulbar block local anesthesia Graefes Arch Clin Exp Ophthalmol 1997 May 235(5):277 82 9176675
Suzuki R, Kuroki S, Fujiwara N, et al The effects of phacoemulsification cataract surgery via local anesthesia on preoperative and postoperative blood pressure levels Ophthalmology 1997 Feb 104(2):216 22 9052625
Sweeney EJ, Barber K, Prosser JA A comparison of percutaneous and perconjunctival routes of administration of peri-ocular anaesthesia for day case cataract surgery Anaesthesia 1993 Apr 48(4):336 8 8494140
Teichmann KD, Uthoff D Retrobulbar (intraconal) anesthesia with a curved needle: Technique and results J Cataract Refract Surg 1994 Jan 20(1):54 60 8133481
Thomson I Addition of hyaluronidase to lidocaine with adrenaline for retrobulbar anaesthesia in the surgery of senile cataract Br J Ophthalmol 1988 Sep 72(9):700 2 3052572 1041560
Thorburn W, Thorn-Alquist AM, Edstrom H Etidocaine in retrobulbar anaesthesia. A comparison with mepivacaine Acta Ophthalmol (Copenh) 1976 Oct 54(5):591 600 358319 790888
Tseng SH, Chen FK A randomized clinical trial of combined topical-intracameral anesthesia in cataract surgery Ophthalmology 1998 Nov 105(11):2007 11 9818597
Ursell PG, Spalton DJ The effect of solution temperature on the pain of peribulbar anesthesia Ophthalmology 1996 May 103(5):839 41 8637697
Uusitalo RJ, Maunuksela EL, Paloheimo M, et al Converting to topical anesthesia in cataract surgery J Cataract Refract Surg 1999 Mar 25(3):432 40 10079452
van Rij G, Renardel de Lavalette JG, Baarsma GS, et al Effect of oxybuprocaine 0. 4 percent in preventing surgically induced miosis Br J Ophthalmol 1984 Apr 68(4):248 51 6367812 1040307
Vettese T, Breslin CW Retrobulbar anesthesia for cataract surgery: Comparison of bupivacaine and bupivacaine/lidocaine combinations Can J Ophthalmol 1985 Jun 20(4):131 4 4052861
Virkkila ME, Ali-Melkkila TM, Kanto JH Premedication for outpatient cataract surgery: A comparative study of intramuscular alfentanil, midazolam and placebo Acta Anaesthesiol Scand 1992 Aug 36(6):559 63 1514342
Virkkila M, Ali-Melkkila T, Kanto J, et al Dexmedetomidine as intramuscular premedication in outpatient cataract surgery. A placebo-controlled dose-ranging study Anaesthesia 1993 Jun 48(6):482 7 8100688
Virkkila M, Ali-Melkkila T, Kanto J, et al Dexmedetomidine as intramuscular premedication for day-case cataract surgery. A comparative study of dexmedetomidine, midazolam and placebo Anaesthesia 1994 Oct 49(10):853 8 7802178
Virkkila M, Ali-Melkkila T, Soini H, et al Pharmacokinetics and effects of i. m. alfentanil as premedication for day-case ophthalmic surgery in elderly patients Br J Anaesth 1993 Oct 71(4):507 11 8260298
Virtanen P, Huha T Pain in scleral pocket incision cataract surgery using topical and peribulbar anesthesia J Cataract Refract Surg 1998 Dec 24(12):1609 13 9850899
Walker AK Neuroleptanalgesia for intra-ocular surgery: Experience in a developing country Anaesthesia 1976 Jun 31(5):690 4 945704
Waller SG, Taboada J, O'Connor P Retrobulbar anesthesia risk. Do sharp needles really perforate the eye more easily than blunt needles? Ophthalmology 1993 Apr 100(4):506 10 8479708
Walters G, McKibbin M The value of pre-operative investigations in local anaesthetic ophthalmic surgery Eye 1997 11(Pt 6):847 9 9537143
Wang HS Peribulbar anesthesia for ophthalmic procedures J Cataract Refract Surg 1988 Jul 14(4):441 3 3404430
Weiss JL, Deichman CB A comparison of retrobulbar and periocular anesthesia for cataract surgery Arch Ophthalmol 1989 Jan 107(1):96 8 2910293
Whitsett JC, Balyeat HD, McClure B Comparison of one-injection-site peribulbar anesthesia and retrobulbar anesthesia J Cataract Refract Surg 1990 Mar 16(2):243 5 2256971
Wolf G, Lynch S, Berlin I Intraocular surgery with general anesthesia Arch Ophthalmol 1975 May 93(5):323 6 1147803
Wong DH, Koehrer E, Sutton HF, et al A modified retrobulbar block for eye surgery Can J Anaesth 1993 Jun 40(6):547 53 8403122
Wong DH, Merrick PM Intravenous sedation prior to peribulbar anaesthesia for cataract surgery in elderly patients Can J Anaesth 1996 Nov 43(11):1115 20 8922766
Wood G, Simpson T The effect of hyaluronidase on the speed of onset of retrobulbar anaesthesia Can J Anaesth 1990 May 37(4 Pt 2):
Yee JB, Burns TA, Mann JM, et al Propofol and alfentanil for sedation during placement of retrobulbar block for cataract surgery J Clin Anesth 1996 Dec 8(8):623 6 8982887
Yee JB, Schafer PG, Crandall AS, et al Comparison of methohexital and alfentanil on movement during placement of retrobulbar nerve block Anesth Analg 1994 Aug 79(2):320 3 7639372
Zehetmayer M, Radax U, Skorpik C, et al Topical versus peribulbar anesthesia in clear corneal cataract surgery J Cataract Refract Surg 1996 May 22(4):480 4 8733854
Zehetmayer M, Rainer G, Turnheim K, et al Topical anesthesia with pH-adjusted versus standard lidocaine 4% for clear corneal cataract surgery J Cataract Refract Surg 1997 Nov 23(9):1390 3 9423913